# Future Research

In our review of the evidence on the barriers and drivers of the use of interactive consumer health IT by the elderly, chronically ill, and underserved populations we identified several areas for future work. The most pressing need is for a principled taxonomy of interactive consumer health IT and related interventions, so that the resulting outcomes of studies involving these systems can be better interpreted by understanding effects of the various components. Currently, it is difficult to generalize across the wide variety of systems. Similarly, future research is needed to understand best practices for the design and implementation of these interactive health technologies for patients. A clear taxonomy will facilitate this effort.

In addition to standardizing our descriptions of the variety of interactive consumer health IT applications, it will be important to develop standardized and clear definitions of the intermediate outcomes relating to the use of these technologies. For example, in the studies we reviewed, system usage has been measured by logins, Web clicks, or time within a session. These varied measures, along with differing expectations for use for each system, make it difficult to compare usage between systems in a meaningful way. The issue gains relevance as the field strives to determine if the measurement of the health technology usage can serve as a means of determining individual engagement, activation, or preference, and whether it can serve as a proxy for intervention exposure or “dose.”

Finally, there is a paucity of research with direct comparison of the use and outcomes of these technologies by the general population versus disadvantaged populations, such as minorities, low-income groups, elderly, disabled, and geographically remote populations. It would be very useful to test the same technology, protocol, and implementation interventions with comparison populations within the same study, to truly understand the barriers and drivers associated with these interventions.