# Discussion

The results of our analysis of the literature pertaining to the barriers and drivers to the use of interactive consumer health IT by the chronically ill, elderly, and underserved is based on the relationships modeled in our analytic framework. As described in the methods section, we modeled the factors that influenced the degree of use of health IT as arising from patient characteristics, technology characteristics, and environmental factors. Our key questions were then generated to test these relationships, as well as the assumption that increased or improved use of the systems would improve intermediate outcomes, such as knowledge, self-efficacy, or health behaviors, as well as end outcomes, such as quality-of-life, satisfaction with care, or costs.

The summarization of evidence described in this chapter is based on Denyer^23^ and Popay's^22^ frameworks. For each of our five key questions, we first analyzed a subset of the papers to develop a model of how best to describe the technologies and interventions, as well as to describe the use characteristics and associated issues. This preliminary synthesis served as a framework for the rest of our summarization. Our focus in this review was on consumer health IT that was interactive, meaning that the consumer or patient was the primary user of the system and received computer-mediated patient-specific information in return. Through our review process, we found distinct technology types that needed to be assessed separately:

- In-home monitoring, disease management, and self-management systems.
- Online forums on health topics.
- Patient access to their EMR and patient/physician e-mail.
- Single or sporadic use of an interactive educational system.
- Interactive training systems that monitor patient signals and provide immediate feedback.
- Interactive and tailored reminding systems.

There are several challenges to reviewing interventions based on interactive consumer health IT, primarily due to the fact that the interventions being studied in the articles we reviewed were highly varied. Firstly, the underlying technology varied significantly and could include Web-based applications, hand-held PDAs or cell phones, and touch-screen computers or kiosks. Secondly, the systems were designed for a wide variety of purposes, not a single intervention. Even though we focused the review on systems for the elderly, chronically ill, and underserved populations, we covered many application areas, such as systems for diabetes, asthma, cancer, mental disorders, smoking cessation, and medication reminding. Children with chronic conditions were included in our review, and we found that they have very different types of usage issues and systems designed for them. Thirdly, the frequency of intended use of the various systems could be quite different. Some were single use interactive educational systems or decision aids. Others were intended for daily use in the home. Fourth, these systems varied widely in complexity, from simple systems providing a single function to complex systems with an robust suite of diverse features. Finally, the embedded care protocols and the degree to which clinicians participated on the other end differed dramatically from study to study. All of these issues are critical when interpreting the results of these studies, and the variability in approaches has made us cautious in generalizing our results too broadly.

Another issue we confronted in reviewing studies of interactive consumer health IT involved the quality ratings for our evidence. We incorporated two quality ratings, one based on the appropriateness of the methodology to the study question and the second based on the quality of the study execution. We based our ratings on a number of systems appropriate for rating evidence pertaining to our key questions on system usage and outcomes.^18,^ ^19,^ ^163^ However, for the key questions on usability, barriers, and drivers to system use, we needed to consider the quality of the evidence for those components of the study separately. Although some articles directly addressed these issues, in most cases our evidence for usability, barriers, and drivers came from studies where these issues were not a key part of the study design, but rather qualitative evidence that accompanied an outcomes study. For these studies we did not formally rate the quality of the evidence on usability, barriers, and drivers separately.

The technologies and interventions we reviewed were typically “leading edge” and not in routine clinical use. Complex interventions such as these are difficult to deploy on a limited budget, especially in an academic setting. One of the primary barriers to system use in the studies we reviewed was that many users had technology malfunctions of some sort. Under these circumstances, it is difficult to determine whether the results of the study are representative of a more polished and tested intervention. Our evidence review of health IT has a smaller percentage of studies rated as high quality, compared with reviews of more straight-forward interventions, such as a pharmaceutical therapy. Yet this is appropriate for studies of evolving technologies. Devoting resources for a large randomized controlled trial of a complex technology early in its development stage is not warranted. Stead et al. proposed guidelines for matching the level of evaluation to the stage of development.^154,^ ^164^ For example, as systems move from specification to component development to combining components and integrating them into the environment, the appropriate evaluations move from laboratory bench tests to tests of validity and then efficacy in the field. But it is only when systems have gone through thorough quality assurance and piloting in the field that large studies designed to provide high quality outcomes information are warranted. Many of the studies we reviewed for the barriers and drivers to the use of health IT were in the relatively early stages of development and not in routine clinical use. Thus, these studies often involved a small number of subjects and measured intermediate outcomes. Additionally, the information on barriers and drivers often came from qualitative additions to studies and not the main study design.

## 4. a. Use of Interactive Consumer Health IT

Findings regarding usage of interactive consumer health IT need to be interpreted with regard to the intended frequency of use of the system. For example, self-management and monitoring systems may be intended to be used on a regular and continuing basis, whereas many of the educational systems we reviewed were intended to be used only once. Availability was also an issue. Some systems were only available to patients in their clinician's office. However, in studies of interventions with multiple components we were able to observe the relative frequency of patient access. For example, from these studies we found that online peer discussion and bulletin boards were the functionalities used most frequently compared with patient interactions with self-management, self-monitoring, health educational, or ask-an-expert functions within the same system. However, in general, self-management tools and systems with ask-an-expert modules were used frequently by subjects in the studies.

In general, we have found that the measurement and understanding of the usage of interactive consumer health IT has begun to be addressed, however, there remains a lack of clarity or standardized metrics. These varied measures, along with differing expectations for use for each system, presents challenges in comparing usage between systems in a meaningful way. The issue gains relevance as the field strives to determine if the measurement of health technology usage can serve as a means of determining individual engagement, activation, or preference, and whether it can serve as a proxy for intervention exposure or “dose.”

The findings describing the frequency of health IT usage (mean logins per subject per month) suggest that certain interactive consumer health IT functionality —peer group support, bulletin board, and secure messaging—may be associated with greater usage by subjects. Patient and consumer surveys have identified peer support (e-groups, chat rooms) as desirable services, providing anytime social support and person-to-person interaction.

It also seems reasonable that some types of interactive consumer health IT would be expected to be used only on an intermittent or ad-hoc basis—shared access to electronic records, or messaging alone added to automatic paging—and not be used as frequently as social support and self-management applications.

## 4. b. Usefulness and Usability of Interactive Consumer Health IT

A great number of home care patients who require disease management are elderly and/or have functional limitations, such as reduced sensory, cognitive or motor capabilities. Although the Internet has the potential to revolutionize the process of health care delivery and empower patients to become more active in the care process, the fastest growing segment of the U.S. population— i.e., people over the age of 50 years—are at a disadvantage because designers of both software and hardware technology fail to consider them as a potential user group.^14^ Usability and accessibility issues are important quality criteria for Web-based interventions, but are frequently ignored by designers and evaluators.^15^ The design of a usable Web-based information system for healthy users who are familiar with computer technology is a challenge. When a system needs to address age-related constraints and the functional limitations of inexperienced users, it becomes even more difficult. Designers of systems for home care patients should aim to increase functional accessibility^165^ and employ rigorous usability testing methods.

Only two of the studies we reviewed were primarily targeted at discovering usability issues, and no studies compared the usability of more than one system at a time, or across populations of users. However, in all studies reporting usability results, a majority of the users found the systems under study to be helpful or useful. Often this was true for more than 90 percent of users.

People with diabetes tended to have vision problems and were concerned about clarity and size of graphics. Several systems required improvements in the display contrast, use of color, and button size. In general, there was a need for clearer and simpler graphics for t older users or those with chronic disabilities. Often the largest usability changes needed to be made with regard to the data entry screens on Web-based systems, although in some cases it was the graphic feedback for home monitoring data that needed improvements in clarity. An additional general finding was that it was important to minimize the need for a user to jump from screen to screen. Researchers found that it was important to keep frequently used items on the main Web page with “one-click” access to important information or data entry screens. Overall, we saw that the usability findings pointed to needing to keep systems simple and free from distracting elements. These issues were particularly relevant for older users and those with functional limitations, however, the findings were still important across all populations.

## 4. c. Barriers to the Use of Interactive Consumer Health IT

Our summary of the evidence on the barriers to the use of interactive consumer health IT pointed mainly to issues of motivation, access, ease of use, and convenience. Most importantly, if users did not perceive a potential health benefit (regardless of an actual benefit or not) they were less likely to use the system. Additionally, if consumers or patients did not already know how to use computers, and especially if they did not have easy access to a computer in their home, there tended to be difficulties in using the intervention.

Many of the technology interventions being studied suffered from usability and technology problems that prevented routine use as intended. Many systems were deployed for evaluation before sufficient quality testing to ensure that even motivated participants could use them. Common technology problems included unreliable Internet access, system crashes, and battery issues. Many of the systems also required updates to fix displays that generated confusion on the part of the users. Oftentimes these issues were not caught in advance of full deployment in a study.

Feedback on the lack of use of some systems often pointed to the difficulty of finding a convenient time or situation to interact with the system. Similarly, data entry on the part of patients was often viewed as cumbersome and too time consuming. Interfaces for reminding systems for medications or for chronic disease management were particularly difficult to implement in a way that would encourage sustained use.

One interesting barrier to use of some disease management or interactive self-management systems that provided either recommendations or changes in treatment based on computer protocols was a lack of trust on the part of some patients. If the system's recommendation did not fit with the patient's mental model or perception of the situation, the patient was unlikely to comply with the advice. In general, if patients did not trust the technology they were less likely to use the system or manage their health in accordance with the recommendations.

Some of the interactive consumer health IT reviewed involved the participation of a clinician as part of the intervention. This could range from secure physician e-mails to a patient, supplemental phone interactions in addition to tailored computer feedback, or clinician review of monitoring data. For interventions where patients expected clinician interaction and did not receive timely responses, usage of the system and satisfaction on the part of the patient tended to drop. These studies reported that a barrier to the successful implementation of these technology interventions was the lack of appropriate resources and workflow modifications for the health care professionals. They identified issues of the lack of reimbursement for e-health encounters and the perception of additional time required. In general, cost was often mentioned as a barrier to system use on the part of both the patient and the health care provider.

In the studies we reviewed, we did not find direct evidence for differential use of the interactive consumer health IT by populations in rural or frontier areas, minorities, low-income groups, or low education groups. There was weak evidence for age being a barrier to anticipated future use of some interventions.

As mentioned in the previous section, usability issues plagued many studies and would also be considered to be a barrier to use. Older age was associated with lower usage in some studies of systems addressing chronic diseases, such as diabetes where vision and other functional disabilities required improved screen contrast and font size. In most studies, these issues were identified as barriers after the system had been deployed.

## 4. d. Drivers to the Use of Interactive Consumer Health IT

Patient perception that the system was helping them appeared to be the most important driver of system use. Generally, these were perceived health benefits. For applications that dealt with sensitive health topics, such as HIV/AIDS, patients identified the anonymity and nonjudgmental nature of interacting with a computer system as a benefit. Other perceived benefits, such as better understanding their doctors and the medical system, were also identified as drivers of technology use.

A further driver corresponding to one of the identified barriers included information from studies where the care protocols involved clinician participation. They found that a rapid response from the participating clinician improved patient satisfaction and sustained use of the system.

One important driver of system use identified in many studies was delivery of the intervention on familiar devices used by consumers or patients every day for other purposes. For example, cell phones with SMS messaging worked especially well for younger ages, and people who routinely used a computer throughout the day anyway would have an easier time adhering to protocols for interactions with self-management systems on the Web. In general, we found that it was important that patients feel the systems were convenient and easy to use, especially for interventions that required frequent sustained use. A particular driver for older individual's use of new technologies was to have an implementation that provided a gradual stepwise introduction to the technology. Finally, several studies identified the tailoring of delivered content as a driver of patient satisfaction, perceived benefit, and system use.

## 4. e. Effectiveness of Interactive Consumer Health IT

Ongoing self management support for chronic conditions was effective if it included a ‘closed feedback loop.’ Among the studies we reviewed, including 13 randomized trials and three studies with other designs, we found that consumer health IT systems that provided a complete feedback loop were generally effective at improving outcomes in chronic conditions. These systems included a combination of (a) monitoring and transmission of data about the current status of the patient; (b) interpretation of this data in light of previously established treatment goals or published guidelines; (c) adjustment of medications, diet, or patient education as required; (d) timely communication back to the patient of recommendations, advice, or information appropriate to their current state, and (e) regular repetition of this cycle. This process is analogous to the familiar Deming-Shewhart cycle for process improvement that serves as the basis for continuous quality improvement in healthcare.^166^ These systems provide the means for continuous improvement through repeated refinement or adjustment of the management of the patient according to their current condition. We observed this pattern across a spectrum of chronic conditions including diabetes, heart failure, hypertension, and asthma. Effective complete feedback loop systems most often incorporated a health professional in the loop—including pharmacists, dieticians, nurses, and physicians—alone or with computer decision support (Table 3), and used a variety of IT, including home computers, voice messaging, text messaging, e-mail, and the telephone.^31,^ ^34,^ ^49,^ ^78,^ ^108,^ ^115,^ ^123,^ ^127,^ ^131^–^133,^ ^135,^ ^136,^ ^139^

Table 3 Examples of complete feedback loop systems

Author, Year, Design | Condition | Monitor Frequency | Feedback Frequency | Feedback Source | Nature of Information
Cho, 2006, RCT^123^ | DM | Daily | Semi-weekly | Clinician e-mail | State-specific
Delgado, 2003, Case series^31^ | CHF | Daily | Daily | Nurse Practitioner Website | State-specific
Glasgow, 2003, Before/After^34^ | DM/Diet | NR | Quarterly | “Automatic feedback” | State-specific
Green, 2008, RCT^127^ | HTN | Daily | Biweekly | Pharmacist | State-specific
Kashem, 2006 RCT^40^ | CHF | > Weekly | > Weekly | RN, MD; phone, system | State-specific
Kim, 2006, RCT^131^ | DM/ACT | > Weekly | Weekly | RN phone | State-specific
Kim, 2007, RCT^115^ | DM | > Weekly | Weekly | RN via SMS and web | State-specific
Kwon, 2004, RCT^132^ | DM | 3×/Week | > Weekly | MD, RN, RD | State-specific
LaFramboise, 2003, RCT^133^ | CHF | Daily | Daily | RN, phone system | State-specific
Noel 2004, RCT^135^ | CHF, COPD, DM | Not clear | Not clear | Nurse case manager advice | State-specific
Rasmussen, 2005, RCT^49^ | Asthma | Daily | Regular | Physician w/CDSS | State-specific
Rogers, 2001, RCT^136^ | HTN | 3×/week | Weekly | Physician, by phone | State-specific
Southard, 2003, RCT^139^ | CHF | > Weekly | Weekly | Web use | State-specific
Turnin, 1992, RCT crossover^108^ | DM | 6×/month | 6×/month | Expert system for diet, calorie analysis | State-specific

In essence, then, this group of closed feedback loop systems are health IT based forms of self-management support of the sort proposed in the Chronic Care Model. Of note, the systems described in the studies we examined depended on active engagement of patients and involvement of health professionals, supported by the specific technology interventions. Questions remain as to (a) the optimal frequency of monitoring, adjustment, and feedback, which are likely to be condition specific; (b) the optimal level of participation by members of the health care team; (c) the degree to which the process depends on familiarity and trust between the patient and the other elements of the system; and (d) the role of support and encouragement, as opposed to refinement of the management plan. Perhaps most challenging, these systems increase the frequency of patient-provider interaction while shifting the location of interaction away from episode-driven office-based care, and no mechanism exists to support these activities under current health care reimbursement mechanisms.

Training or treatment through the use of multiple session or one-time use systems appear to be effective when it includes a similar complete loop of patient-specific information as the basis for tailored advice or education, although the evidence is less strong. Studies of these interactive consumer health IT systems were fewer in number and used weaker study designs, but overall the findings were comparable to the findings for chronic disease self management. Tailoring of information or adjustment of treatment based on patient state appear to be consistent elements in the effective systems, but robust studies of direct comparisons were not identified in this review. Systems providing such training or treatment were effective for patients with asthma,^130,^ ^144^ depression,^143,^ ^149^ and panic/phobic disorder,^97^ while a study with no feedback for patients with breast cancer showed no improvement,^46^ and a study of problem drinkers found face-to-face counseling to be effective while electronic counseling was not.^118^ It is unclear from the evidence available whether these systems will have a sustained impact, and they may be best suited for conditions requiring short-term treatment. Interactive consumer health IT systems that provided peer interaction, alone or as part of multi-component systems, were generally effective for improving intermediate outcomes but not for health outcomes.

Consumer health IT systems that provide monitoring alone or reminding alone were not clearly effective. We found fewer studies of such systems, those identified had weaker study designs, and the evidence from them was not consistent. The heterogeneity of the systems described in these studies and the variety of chronic conditions to which they were applied make it difficult to generalize about their effects or lack of effects. The same can be said for systems that provide access to the EMR when they are not part of a “complete feedback loop”: fewer studies were identified; the studies reviewed employed weaker study designs; and the results did not consistently show benefit, in terms of peer support, self efficacy, or other outcomes (Appendix H *).

* Appendixes and Evidence Tables cited in this report are available electronically at http://www.ahrq.gov/clinic/tp/hitbartp.htm

## 4. f. Use of Interactive Consumer Health IT by Populations of Interest

Each of our key questions had sub-questions about the relative use and effectiveness of the technology by key populations (elderly, chronically ill, and underserved). However, we did not find evidence for relative comparisons between groups of interest on the same technology. There were certainly studies that primarily focused on special populations, such as a specific minority group, a low income area, an elderly population, or a rural setting, but they did not answer questions of relative use and outcomes.

## 4. g. Technical Difficulties Interfering With Evaluations

Of the studies of interactive consumer health IT reporting health outcomes, nine studies were compromised by technical problems that limited use by patients and limited evaluation by investigators, several of which had to be excluded on this basis. Depressed patients withdrew from a randomized trial of a self-help system, with 21 of 57 reporting the system was too demanding and only 65 percent completing all modules.^143^ Elderly heart failure patients had difficulty getting medications out of a reminder device and reported difficulty reading the screen, limiting potential effect on medication adherence.^106^ After initial enthusiasm, adult patients with diabetes failed to enter data, and only one of six entered data for three consecutive weeks as required for the study, citing loss of Internet connection and difficult-to-use data entry screens.^29^ Adults with asthma had higher adherence to peak flow monitoring using a paper diary than an Internet-based log, citing problems with Internet connection, system errors, and other technical problems, though subjects retained a positive attitude toward Internet monitoring.^30^ Geriatric diabetic patients had limited benefit from a voice message system, citing difficulty using buttons on the mobile phone and lost connections.^145^ Of 30 COPD patients, 14 dropped out because of technical and other difficulties using the system.^113^ An interactive voice response system failed to reach 30 percent of smokers after cardiac hospitalization and only 18 of 50 patients actually received all three calls,^50^ while another IVR system frequently failed to reach veterans with diabetes.^47^ Of 56 obstructive sleep apnea patients one in seven was unable to use the device to monitor sleep and CPAP use.^107^ In contrast, systems without such technical problems enjoyed more complete and effective use and a more robust evaluation.