# Methods

## 2. a. Technical Expert Panel Input

Eight individuals with relevant expertise served on the Technical Expert Panel to help define the scope of the project, provide feedback on our analytic framework and key questions, and weigh in on other critical issues throughout the project (Appendix A *). We specifically elicited feedback on definitions of the populations of interest (e.g., who constitutes underserved and vulnerable populations), important chronic illnesses, examples and definitions for interactive consumer health information applications, and significant barriers, drivers, and outcomes. The experts also helped to identify sources of unpublished (gray) and difficult-to-find literature and relevant databases.

* Appendixes and Evidence Tables cited in this report are available electronically at http://www.ahrq.gov/clinic/tp/hitbartp.htm

## 2. b. Key Questions and Analytic Framework

Our preliminary key questions were developed by AHRQ and edited based on feedback from our team, the Technical Expert Panel, and AHRQ. The final key questions listed below were used to guide the systematic review process.

1 Among elderly, chronically ill, and underserved populations, what is the current level of use of specific forms of interactive consumer health IT?
  a What are the primary uses of interactive consumer health IT?
  b How does interactive consumer health IT use vary?
  c Does use vary in settings where consumers have access to interactive health IT tools?
  d How does the level and type of health IT use for the elderly, chronically ill, and underserved populations compare with that of the general population?
2 In the elderly, chronically ill, and underserved populations, what type of interactive consumer health IT is most useful and easy for people to use?
  a How useful are various types of interactive consumer health IT applications?
  b What are the usability factors associated with various types of interactive consumer health IT?
3 In the elderly, chronically ill, and underserved populations, what barriers hinder the use of consumer health IT?
  a How do these barriers vary for these populations of interest?
  b How do these barriers vary by type of interactive consumer health IT application?
4 In the elderly, chronically ill and underserved populations, what drivers or facilitators may stimulate or enable the use of consumer health IT?
  a How do these drivers and facilitators vary for these populations of interest?
  b How do these drivers and facilitators vary by type of interactive consumer health IT application?
5 In the elderly, chronically ill, and underserved populations, is interactive consumer health IT effective in improving outcomes?
  a How does the technology's effectiveness vary for our populations of interest?
  b How does the technology's effectiveness in these populations of interest differ from the effectiveness in the general population?

The analytic framework (Figure 1) is a graphic representation^18^ of the relationships among the populations, interventions, and outcomes examined in the key questions, along with potential barriers and drivers to health IT. We categorized barriers and drivers as: (1) patient characteristics, (2) attributes of the health IT, and (3) environmental factors. The Technical Expert Panel worked with us to refine the analytic framework, as well as to further clarify our definitions of patient populations, technologies, and settings of interest.

Figure 1. Analytic Framework

Note: Analytic framework for the use of health IT by the elderly, chronically ill, and underserved. Solid arrows represent relationships among variables in the framework where we systematically searched for evidence. Dashed arrows represent well-established relationships outside the scope of this review. The circled numbers indicate key questions.

## 2. c. Population

Populations examined in this review (Table 1) include the elderly, chronically ill, and underserved. Elderly was defined as mean age greater than 65 years, or functionally elderly as agreed upon by the reviewers. In considering populations with chronic illnesses, we included conditions that patients had for more than one year and that would benefit from ongoing monitoring or treatment. This included conditions such as diabetes, asthma, heart failure, chronic obstructive pulmonary disease, as well as mental illnesses. We also included disabilities where there was an impairment in body function or structure that interfered with a patient's activities. We defined underserved populations as those with an inhibited ability to receive either medical or information services. This included underserved minorities, low-income populations, and medically underserved geographic regions.

Table 1 A summary of populations included in this review

Populations | Potential Categories | Description
elderly | elderly | over 65 years of age
functionally elderly | by life experience or health concerns; need clarity/inter-observer agreement
chronically ill or disabled | chronic condition | more than 1 year and benefits from ongoing monitoring or treatment
chronically ill or disabled | impairment | impairment in body function or structure
chronically ill or disabled
activity limitation | difficulty in executing activities
participation restriction | problems experienced in participating in life situations
underserved | medically underserved population or medically underserved area | study uses Bureau of Health Professions / Health Resources and Services Administration designated medically underserved population or medically underserved area
underserved | medically underserved area | region where individuals are inhibited in their ability to receive services
underserved group | population which is inhibited in its ability to receive medical or information services

## 2. d. Technology

Our review focused on highly interactive technologies, intended primarily for use by patients or consumers, that incorporated both patient interaction and patient-specific feedback (Table 2). Examples of included technologies are self-management and monitoring systems with tailored health advice; personal medical records or access to personal data in a provider EMR; health games that adapt to patient conditions; interactive online support or chat groups; and sites with storage, indexing, retrieval, display, or advanced features (summarization and decision support).

Table 2 Health IT inclusions and exclusions

Include: Health IT program where:; - Patient interacts with the technology,; - Computer/technology processes the information in some way, and; - Patient receives information in return or has access to patient-specific information.; - Examples: tailored health advice; clinic-linked personal health record/access; risk assessment tools, health calculators, predictive tools; interactive online support or chat groups; health games that adapt to the patient (more than simple “next page”); programs or sites with storage, indexing, retrieval, display, or advanced features (summarization and decision support).
Exclude: Health IT program where:; - Limited or no patient or consumer driven involvement or; - Web browsing of general health information databases or; - Patient-clinician communication without computer information support (simple videoconferencing or phone) or; - Systems where the patient interacts but doesn't receive patient-specific information back (e.g., electronic survey - no feedback) or; - Systems primarily or entirely for health professionals or caregivers; - Examples: passive monitoring; direct video or phone conferencing; general Web-based content (e.g., WebMD, MedlinePlus®, etc.); education, information-based only programs; electronic surveys without feedback; frequently asked question sites; tele-visit that replaces the face-to-face interaction with a clinician; video interaction

Technology interventions were excluded if they had limited or no patient-driven involvement, if the interactions were without computer information support, or if they did not provide patient-specific information to patients (e.g., Web browsing of general health information databases). Systems primarily or entirely for health professionals or caregivers were also excluded. Examples of excluded technologies include: passive monitoring without interactive feedback, information Web sites such as WebMD and MedlinePlus®, frequently-asked-question Websites, simple video or phone conferencing, non-tailored education-information only programs, or electronic surveys without feedback.

## 2. d. i. Further Refinement of Technologies

Some health IT interventions fit our inclusion criteria, but either had minimal tailoring of information, or minimal patient interaction with the system. Minimal tailoring included educational systems that primarily tailored the interaction based on the user's knowledge or interest, and minimal interaction included high-technology tailored reminding systems with patient-specific information but where patients had not entered or requested information. This led us to develop a method of grouping the technologies based on how they clustered along two axes: (1) the degree to which the system assessed patient-specific information and (2) the degree to which the system conveyed patient-specific recommendations (Figure 2).

Figure 2. Spectrum of Information Interventions

Note: This diagram illustrates how various health information technologies differ to the degree in which they encode information about the patient (along the abscissa) and the degree to which they provide patient-specific recommendations back to the user (along the ordinate). Our technologies of interest did both (lighter colored ellipses).

We excluded health IT systems such as general health Websites and practice guidelines (at the far left of Figure 2) as they did not both assess and produce patient-specific information. We also excluded monitoring only systems (at the bottom of Figure 2) as these systems transmit information to providers but do not require patient interaction or provide the patient with information. The most relevant systems to this review are in the far upper right of this diagram and include self management systems where patients input information about themselves and receive tailored feedback in response. Studies examining these systems received full abstraction and review. Other types of interventions—such as high-technology reminding, education with minimal tailoring, one-time-use decision aids, and online forums—were summarized qualitatively.

## 2. e. Outcomes

We included studies reporting any of a broad spectrum of outcome measures, including technology use, health related behaviors, health service utilization, disease status, quality of life and functional outcomes

## 2. f. Study Designs

We included a broad spectrum study designs in this review, appropriate to the nature of our key questions. Whereas randomized controlled trials (RCTs) are considered optimal for the assessing the impact of specific interventions on outcomes, other study designs were more appropriate to answer other questions, such as epidemiologic studies to address rates of use of interactive consumer health IT, and qualitative or usability methods to address questions regarding barriers and drivers, or usability. We included only reports of original studies and excluded letters, editorials, opinion pieces, news items, and commentary.

We confined this review to studies where the full-text was available in English. We identified foreign language articles with an English abstract to determine if they contained relevant data but did not find any relevant studies that required translation.

## 2. g. Data Sources and Search Strategy

Our search for the published literature included structured searches of both standard and specialty bibliographic databases. We searched MEDLINE® (1950–Nov 2007), CINAHL® (1982–Feb 2008), PsycINFO® (1806– Feb 2008), the Cochrane Controlled Trials Register and Database of Systematic Reviews (1^st^ quarter 2008), ERIC (1960–March 2008), and the American Association of Retired Persons (AARP) Ageline® (1978–Dec 2007). Although all database search coverage predated 1990, we focused our review on citations from 1990 to present. Detailed searches and time periods covered are found in Appendix B ^†^.

† Appendixes and Evidence Tables cited in this report are available electronically at http://www.ahrq.gov/clinic/tp/hitbartp.htm

We also examined the reference lists of key included studies and members of the TEP provided input on additional citations. We examined relevant systematic reviews retrieved from our searches for further citations.

## 2. h. Inclusion and Exclusion of Literature

In all, 8,522 English abstracts were examined and 563 full-text papers were examined for inclusion by two reviewers using refined inclusion and exclusion criteria (Appendix C). Disagreements between reviewers were resolved by discussion and consensus. Appendix D provides details on the number of captured titles and abstracts and the number of full text papers reviewed for each key question. A listing of the studies excluded after full text review are in Appendix E.

## 2. i. Data Abstraction

Based on the criteria in Appendix C, we included 129 unique publications for data abstraction. All included studies were abstracted into evidence tables. Data abstracted included study design, recruitment procedures, characteristics of the population, and details on the intent and implementation of the intervention. All data on outcomes including technology use, health related behaviors, health service utilization, disease status, quality-of-life and functional outcomes were abstracted. Many studies applied to more than one question.

## 2. j. Quality Rating of Studies

Each study was assessed for internal validity using quality rating criteria developed by the United States Preventive Services Task Force,^18^ and the Common Drug Review Process.^19^ Factors such as adequate randomization, allocation concealment, baseline comparability of participants, blinding, and low loss to follow-up were used to assess potential study bias.^19,^ ^20^ For Key Question 5, which addressed the impact of interactive consumer health IT on outcomes, systematic reviews, randomized controlled trials, cohort studies, and case control studies were included and rated as good, fair, or poor.^18^ Other studies designs, often using qualitative methods, were considered for key questions on usage, usability, barriers, and drivers. Although our team reviewed criteria for rating qualitative study designs,^21^ these methods did not lend themselves to also addressing the qualitative secondary outcomes of the effectiveness studies. Thus, we did not formally rank each qualitative study (Appendix F) and incorporated evidence from all studies with information on usability, barriers, and drivers.

## 2. k. Data Synthesis

We focused our synthesis on interactive consumer health IT for which the patient interaction with the technology was significant and frequent and where subjects received patient-specific information in return. For these technologies, we fully abstracted the data and performed quality assessment. For educational systems with minimal tailoring, as well as for training and reminding systems, we abstracted only major results and provided a separate summary of those findings.

We reviewed and summarized our findings based on suggested approaches for developing both frameworks (as recommended by Popay and colleagues)^22^ and field design propositions or guidelines for working with evidence from disparate technologies.^23,^ ^24^ This approach provided an opportunity to obtain an inferred set of findings that transcended individual cases.^23^ Design propositions such as patient, environment, and technology characteristics; how and to what degree the patients or consumers used the technology; and intermediate and final health outcomes were included.

After studies were abstracted and assessed for quality, the investigators rated the strength of the body of evidence for each key question, also according to the criteria outlined by the Guide to Community Preventive Services.^25^ In assessing quality at the key question level, investigators considered aggregate internal validity, aggregate external validity, and coherence and consistency. The quality and quantity of the studies and size and consistency of the results were used to grade the overall strength of the evidence.

## 2. l. Peer Review

We identified five individuals to serve as peer reviewers of our draft evidence report, including those with a range of personal, clinical, and professional interests in the use of health IT. Four federal organizations and four professional societies were also asked to review the draft report (Appendix G).