# Introduction

## 1. a. Goal of the Report

In response to a recommendation given to the U.S. Secretary of Health and Human Services by the American Health Information Community's Chronic Care Workgroup, the Agency for Healthcare Research and Quality (AHRQ) contracted with Oregon Health & Science University's Evidence-based Practice Center to generate an evidence report on the barriers and drivers to the use of health information technology (health IT) by the elderly, those with chronic illness or disabilities, and the underserved. This report describes factors influencing the use and usability of interactive consumer health IT in these populations. It also summarizes the scientific evidence on outcomes of using these technologies, identifies gaps in the evidence, and provides a context for future inquiry. The report's primary focus is to identify barriers and drivers to use in these populations and to characterize the features of the technology interventions that relate to improved outcomes for these specific populations.

## 1. b. Background

A promising aspect of interactive consumer health IT is the potential to engage and support consumers in their own care by integrating their health information needs and preferences into information systems. Such technologies provide targeted or tailored health information and/or self-care management tools or applications designed to support patients' or consumers' management of their health, health care, or health information. It is important to understand whether and how populations such as the elderly, chronically ill (including individuals with disabilities and individuals who need chronic care or end-of-life care), and underserved populations (e.g., inner-city/rural, low income, minority, etc.) will be able to access, use, and benefit from health IT.

The health care needs of these populations are growing, and health information management tools have the potential to improve access to relevant health information, facilitate communication between patients and providers, and support chronic disease management. There is an opportunity to help bridge health disparities for these populations. In order to develop and provide appropriate and effective approaches, we need to understand the barriers and drivers of health IT use for these populations. Potential barriers and drivers of health IT use include motivation, cost, access to technology, literacy, education, language, culture, or telecommunication infrastructure.

The American Medical Informatics Association (AMIA) Working Group on Consumer Health Informatics defines consumer health informatics as electronic information and communication technologies that patients/consumers use to improve their medical outcomes and/or participate in their health care decisionmaking process.^1^ In addition, consumer health IT may assist individual consumers in gathering, understanding, and sharing health information with their providers.^2^

Interactive consumer health technology applications have had an increasingly important role to play in health care. Recent work based on the Institute of Medicine's Crossing the Quality Chasm report^3^ has focused on fostering self-management support by encouraging providers to use education and other supportive interventions in order to systematically increase patients' skills and confidence in managing their health problems.^4^ Two of the specific initiatives have to do with patient-centered care and informatics. Patient-centered care aims to inform and involve patients and their families in decisionmaking and self-management, coordinate and integrate care, provide physical comfort and emotional support, understand patients' concepts of illness and their cultural beliefs, and understand and apply principles of disease prevention and behavioral change appropriate for diverse populations. Informatics aims to communicate, manage knowledge, and support decisionmaking using IT.^4^

This evidence review focuses on interactive consumer health IT where patients or consumers interact directly with the technology and receive patient-specific information in return. Examples of these systems include home monitoring technology with interactive disease-management or self-management technology, educational or decision-aid software that is interactively tailored to the patient's needs, online patient support groups, tailored interactive health reminder systems where interactions are linked with electronic medical records, and patient-physician electronic messaging. These types of systems may be implemented on a variety of platforms using Web/Internet technology, desktop computer applications, touch screen kiosks, personal digital assistants (PDAs), cell phones, or combinations of the above.

This review includes care protocols that may or may not involve health care professionals as part of the system, and includes only computer-mediated interactional technology that does more than simply act as a conduit between humans, as in many telemedicine applications. We consider both the specific elements and functions of the technology, as well as the embedded care protocols and implementation features. Many factors relating to how the technology is deployed to the consumer or health system can influence access, usability, and effectiveness.

## 1. c. Burdens of Illness, Conditions, and the Digital Divide

Approximately 120 million Americans have one or more chronic illnesses, accounting for 70 to 80 percent of health care costs. Twenty-five percent of Medicare recipients have four or more chronic conditions, accounting for two thirds of Medicare expenditures.^5,^ ^6^ Most patients with chronic conditions such as hypertension, diabetes, hyperlipidemia, congestive heart failure, asthma, and depression are not treated adequately, and the burden of chronic illness is magnified by the fact that chronic conditions often occur as comorbidities.^7,^ ^8^

One key element of systems-oriented chronic care models is support of patient self-management in the home environment.^9^ Such self-management support can reduce hospitalizations, emergency department use, and overall managed care costs.^7,^ ^8,^ ^10^–^13^ In this evidence review, we specifically examine the factors that influence the use and outcomes of technology designed to empower patients to participate more fully in their health care and health care decisions, with a specific emphasis on understanding the issues for the elderly, chronically ill, and underserved.

A great many elderly persons receiving home care have functional limitations, such as reduced sensory, cognitive, or motor capabilities and may require disease management for multiple chronic conditions. Although health IT has the potential to empower patients to become more active in the care process, the elderly may be disadvantaged unless the designers of both software and hardware technology consider their needs explicitly.^14^ Usability and accessibility issues are important quality criteria for Web-based interventions, but often neglected by designers and evaluators.^15^

Finally, the opportunities afforded by consumer health IT are not equally available to everyone. Both researchers and policy makers have attempted to understand and remedy the link between health disparities and Internet access. Those who most need health information often lack the means, knowledge, and skills necessary to benefit from Internet health resources.^16^ One significant barrier to the use of Internet health resources is consumer access. In 2006, the Pew Internet and American Life Project found that more than one quarter of U.S. adults had no online presence, and many Americans used a slow-speed connection.^17^ Non-users were more likely to be poor, less educated, over the age of 65, disabled, members of ethnic minorities, and non-native English speakers.^17^