# Appendix I. Study Quality Assessment Table with References

## Randomized Controlled Trials

Author | Year | Random assignment? | Treatment allocation concealed? | Groups similar at baseline? | Eligibility criteria specified? | Blinding? | Author | Care provider blinded? | Patient blinded? | High withdrawal/attrition rate? | Was the rate differential by group? | Quality Rating
Andersson | 2003 | Unclear/NR | Unclear/NR | Yes | Yes | Unclear; NR | Andersson | No | No | Yes; 14/44 (31.8%) | No; self-help+telephone=7/24 (29.2%), self-help alone=7/20 (35.0%) | Fair
Andersson | 2006 | Yes | Unclear; NR | Yes | Yes | NR | Andersson | N/A | No | No; 2/64 (3.1%) | No; treatment=2/32 (6.2%), control=0 | Fair
Andersson | 2005 | No | No | Yes | Yes | Unclear | Andersson | No | No | Yes; 32/117=27% | Yes; treatment=21/57 (36.8%) (main reason=treatment too demanding), control=11/60 (18.3%) | Poor
Andrade | 2005 | Unclear | No | Yes | Yes | NR | Andrade | No | No | No | No | Fair
Andrade | 2001 | Unclear | NR | NR | No | NR | Andrade | No | No | NR | NR | Poor
Araki | 2006 | Unclear | NR | Yes | Yes | NR | Araki | N/A | No | No; 1 patient excluded from analysis (missing data on lab) | No | Fair
Armstrong | 2005 | Unclear/NR | Yes | Unclear | Yes | Yes | Armstrong | Yes | Yes | Yes; 5/32 (25%) | Unclear | Fair
Artinian | 2003 | Yes | NR | Yes | Yes | NR | Artinian | No | No | NR | NR | Fair
Bachofen | 1999 | No | No | NA | No | Unclear | Bachofen | No | No | No (0.09%) | NA | Poor
Barnason | 2006 | No; use of lot drawing method | Unclear; NR | Unclear | Yes | Unclear | Barnason | No | No | Unclear; NR | Unclear; NR | Poor
Barnason | 2003 | No; drawing lot used | Unclear; method NR | Yes | Yes | Unclear | Barnason | No | No | Unclear; NR | Unclear; NR | Fair
Barrera | 2002 | Unclear, implied | NR | Yes | Yes | NR | Barrera | N/A | No | Yes; 37/160 (23%); but results of ANOVA showed that those who dropped out were comparable to those who were assessed at T2 | No; 10/40 (25%) in the Support Group condition and 9/40 (22%) in each of the other three conditions | Fair
Block | 2004 | Yes | Unclear; NR | No | Yes | NR | Block | N/A | No | No; 10/491 (2%) | NR | Fair
Carlbring | 2007 | Yes | No | Yes | Yes | Unclear | Carlbring | No | No | No | No | Fair
Cawsey | 2000 | NR | NR | NR | Yes | NR | Cawsey | No | No | NR | NR | Fair-Poor
Chan | 2003 | Yes; random numbers table | NR | Yes | Yes | No | Chan | No | No | No | No | Good
Chen | 2006 | No | N/A | Unclear | Minimal | NR | Chen | No | No | NR | NR | Poor
Cho | 2006 | Yes | No | Yes | Yes | Unclear | Cho | No | No | NR | NA | Good
Christensen | 2004 | Yes | Yes | No; significantly more years of eduction for one group compared to the others (15.0 vs 14.6 vs 14.4, P=0.04) | Yes | NR | Christensen | No | No | Yes; 111/525 (21.1%) | Yes; Treatment group 1=29/165 (17.6%), Treatment group 2=61/121 (33.5%), control=21/178 (11.8%); but did an ITT | Fair
Cruz-Correia | 2007 | Yes | NR | NR, but crossover trial with patients serving as their own controls | Yes | NR | Cruz-Correia | N/A | No | No; 2/21 (9.5%) | Yes: Internet=2/9 (22.2%), Paper=0; but, crossover and analyzed combined treatments periods with noncompleters excluded from both groups | Fair
Estabrooks | 2005 | No | No | Yes | Yes | Unclear | Estabrooks | No | No | Yes | Yes | Poor
Franklin | 2006 | Yes | NR | Yes | Yes | NR | Franklin | No | No | Somewhat; 14/92 (15.2%) were lost to follow-up or discontinued intervention | Somewhat; Group 1=3/28 (10.7%), Group 2=6/33 (18.2%), Group3=5/31 (16.1%) | Fair
Frenn | 2003 | No | N/A | Yes for evaluable population, NR for initial population | No | NR | Frenn | No | No | Yes; 34/137 (24.8%) for physical activity and 48/137 (35.0%) for dietary fat analyses | Unclear; distribution of dropouts NR | Poor
Gega | 2004 | NA | No | Yes | Yes | No | Gega | No | No | Yes (29%) | Unclear | Poor
Glasgow | 2000 | Unclear | Unclear; NR | Yes | Yes | No | Glasgow | No | No | No; 43/320 (13.4%) | Yes; basic=13/80 (16.2%), basic+telephone=13/80 (16.2%), basic+community resources=5/80 (6.2%), combined=12/80 (15.0%) | Fair
Glasgow | 2003 | Unclear; NR | Unclear; NR | No; total cholesterol levels were significantly lower in the one group | Yes | Unclear | Glasgow | No | No | Yes; 18% | No; differences described as “ns”, but data NR | Fair
Green | 2008 | Probably; NR | No; serially-numbered envelopes | No: Significantly fewer females in the one group | Yes | Yes | Green | No | No | No; 48/778 (6.2%) | No | Fair
Guendelman | 2002 | NR | No | Yes | Yes | No | Guendelman | No | No | No; 9% | No; health buddy gorup=4/66 (6.1%), asthma diary=8/68 (11.8%) | Fair
Gustafson | 1994 | NR | NR | NR | Yes | NR | Gustafson | No | No | NR | NR | Poor
Gustafson | 2001 | Unclear | NR | Yes | Yes | No | Gustafson | NR | NR | Yes; 15.5 % in the control group (23 out of 148) and 17 % in the Intervention group (25 out of 147) | No | Fair
Gustafson | 2001 | Unclear | Unclear; NR | Unclear | Yes | No | Gustafson | No | No | No; 19/265 (7.2%) | No; control=7/132 (5.3%), experimental=12/133 (9.0%) | Fair
Gustafson | 1999 | Yes | Yes | Yes | No | NR | Gustafson | No | No | No; 21/219 (9.6%) | No; CHESS=13/107 (12.1%), control=8/97 (8.2%) | Fair
Holman | 1996 | Unclear | Unclear/NR | Unclear/NR | No | No | Holman | No | No | Yes; 16.7% (1 patient) | Yes; 0% in on/off sequence, 33% in off/on sequence | Fair-Poor
Jan | 2007 | NR | No | Unclear | Yes | NR | Jan | No | No | No; 20/184 (10.9%) | Probably not; of 184 “eligible”, 5 families “declined”,then 15 more excluded due to “at the request of the participants” or “lack of data due to internet failure”: intervention=9/97 (9.3%), control=6/82 (7.3%) | Fair
Japuntich | 2006 | Unclear; randomized- no details on approach | Unclear/NR | Yes | Yes | No | Japuntich | No | No | Yes; Chess Group: 47.9% Control Group: 43% | No | Fair-Poor
Jones | 1999 | NR | NR | NR | Yes | NR | Jones | No | No | No; 87/525 (16.6%) | Yes; personal computer=22/178 (12.3%), general computer=39/167 (23.3%), booklet information=26/180 (14.4%) | Poor
Jones | 2001 | Unclear | NR | Unclear; NR | Yes | NR | Jones | No | No | Yes; 66/112 (58.9%); but conducted ITT analysis using LOCF method | No | Fair
Joseph | 2007 | Yes; random number generator | Unclear | Yes | Yes | Unclear | Joseph | No | No | No; 13.0% | No | Fair
Kashem | 2006 | NR | NR | No; SBP and DBP were significantly higher in the control group | Yes | NR | Kashem | No | No | NR | NR | Fair-Poor
Kenwright | 2004 | No | No | Yes | Yes | No | Kenwright | No | No | Yes; (37% in London clinic) | Unclear | Fair
Kenwright | 2005 | Yes; random numbers table | No; opaque envelopes contained numbers | Unclear | Yes | No | Kenwright | No | No | Yes; Scheduled support- 13.6% Requested support- 59% | Yes; 45.4% difference. 2-tailed Fisher's exact test score = .004 | Fair- Poor
Kim | 2006 | NR | NR | Unclear | Yes | NR | Kim | No | No | NR; but 100% included in analyses per Table 2 | NR | Fair
Kim | 2007 | Yes | NR | Yes for completers (n=51); NR for all randomized participants (n=60) | Yes | NR | Kim | No | No | No; 9/60 (15%) | No; intervention=5/30 (16.7%), control=4/30 (13.3%) | Fair
Kosma | 2005 | Unclear/NR | NR | Yes | Yes | NR | Kosma | NR | Somewhat | Yes 50% non-completers Multiple disabilty groups in study | No | Poor
Kressig | 2002 | No | No | NA | Yes | No | Kressig | No | No | No | NA | Fair
Kwon | 2004 | Unclear | NR | Yes | Yes | NR | Kwon | No | No | No; 9/110 (8.2%) | No: intervention=4/55 (7.3%), control=5/55 (9.1%) | Fair
LaFramboise | 2003 | NR | NR | Yes for completers (n=90); NR for all randomized participants (n=103) | Yes | NR | LaFramboise | No | No | No; 12/103 (12.6%) | Unclear; distribution of dropouts NR | Fair
Lahm | 1996 | No | N/A | Yes | No | No | Lahm | No | No | No; all 48 experiments completed | N/A | Poor
Lee | 2007 | No | No | Probably, unclear | Yes | NR | Lee | No | No | Yes; 25% to 28.5%, due to failing to return or having invalid test results, differed depending on outcome | No; intervention=36/144 (25%) to 42/144 (29.2%); control=35/144 (24.3%) to 42/144 (29.2%) | Poor
Leu | 2005 | Yes | Yes | Unclear | Yes | No | Leu | No | No | Yes; 8/50 (16%) | No | Fair
Levetan | 2002 | Yes | NR | Yes | Yes | NR | Levetan | No | No | No; 22/150 (14.7%) | No; 11/75 (14.7%) in each group | Fair
Lorig | 2006 | Unclear | Unclear- not reported | Yes | Yes | No | Lorig | No | No | Y: treatment: 22.5%; usual care: 15% | No | Fair
McKay | 2001 | Unclear; NR | Unclear | Yes | Yes | NR | McKay | No | No | No; 10/78 (12.8%) | Yes; control=7/40 (17.5%) vs intervention=3/38 (7.9%) | Fair
McMahon | 2005 | Yes; random variables generator | Unclear | Yes | Yes | No | McMahon | No | No | Yes; 19.2% | Yes; Control=23.1%, Intervention=15.4% | Fair
McPherson | 2006 | Unclear; method of sequence generation NR | Unclear | No; computer group was older and had more knowledge at baseline | Yes | No | McPherson | No | No | No; 14/101 (13.9%) | No | Fair
Meigs | 2003 | Unclear | Yes | Yes | No | No | Meigs | No | No | Unclear | Yes | Poor
Noel | 2004 | Unclear | NR | More patients in intervention group had caregiver (23% vs 0) | Yes | Unclear | Noel | No | No | Unclear; attrition NR | Unclear; attrition NR | Fair
Owen | 2005 | Yes | NR | No; participants in treatment group were significantly more likely than those assigned to the control group to have received some treatment with a chemotherapeutic agent | Yes | No | Owen | No | No | No; 9/62 (14.5%) | No; intervention=6/32 (18.7%) vs control=3/30 (10%) | Fair
Pike | 2007 | NR | NR | Yes | Yes | NR | Pike | No | No | Yes; 2951/4651 (45.7%); but also reported results of ITT analysis | No | Fair
Rami | 2006 | Unclear | NR | Yes | Yes | NR | Rami | No | No | No; 100% completed | No | Fair
Rasmussen | 2005 | Unclear/NR | No | Unclear | Yes | Unclear/NR | Rasmussen | No | No | Yes; 47/300 (15.7%) | No; (15, 12, 20 subjects, respectively; P=0.26) | Fair
Reid | 2007 | Yes | Yes | No; significantly more patients in the control group completed some post-secondary eduction (P=0.05) | Yes | NR | Reid | No | No | No; 15/100 (15%) | No; UC=8/50 (16%), IVR=7/50 (14%) | Fair
Robertson | 2006 | NA | No | NA | Yes | Unclear | Robertson | No | No | Yes 22 % loss to follow up | NA | Fair
Robertson | 2005 | Unclear | No | Unclear | Yes | Unclear | Robertson | No | No | Unclear | NA | Poor
Rodgers | 2005 | Unclear/NR | Yes | Yes | Yes | Yes | Rodgers | No | No | Yes; 440/1705 (25.8%), but performed ITT analysis with all patients with missing data | No; control=179/853 (21.0%), active=261/852 (30.6%) | Good
Rogers | 2001 | Probably | Yes | No; BMI significantly higher in home service group | Yes | NR | Rogers | No | No | No; 10/121 (8.3%); dropouts included in analyses | No; home service=4/60 (6.7%), usual care=6/61 (9.8%) | Good
Ross | 2004 | Yes | Yes | Yes | Yes | NR | Ross | No | No | Yes for questionnaire returns at 12 months: 26/107 (24.3%), but 15/26 (57.7%) of withdrawals were due to death and all deaths were included in mortality and utilization of health services outcomes | Yes: SPPARO=16/54 (29.6%), Control=10/53 (18.9%) | Good
Ruland | 2003 | Unclear/NR | Unclear/NR | Yes | Yes | NR | Ruland | No | No | No; 7/59 (11.9%) | Unclear; group assignment of withdrawals NR | Fair
Sciamanna | 2005 | Unclear/NR | Unclear/NR | Yes | Yes | Yes | Sciamanna | No | No | N/A; all measurements and interventions were done during a single session | N/A | Fair
Shapiro | 2007 | Yes Randomized block design | No | No | Yes | Yes | Shapiro | No | No | Yes | Yes | Good
Shegog | 2001 | Unclear | Unclear; NR | Yes | No | NR | Shegog | No | No | No; 5/76 (6.6%) | NR | Fair
Smith | 2000 | Unclear | Unclear; NR | Unclear; NR | Yes | Unclear; NR | Smith | No | No | Unclear/NR | Unclear/NR | Poor
Southard | 2003 | Yes | Unclear/NR | Yes | Yes | No | Southard | No | No | No; 4/104=3.8%) | No; SI=4/53 (7.5%), UC=0 | Fair
Stretcher | 2006 | Yes | NR | Yes | Yes | Unclear | Stretcher | NA | Yes | Yes | No | Fair
Stuart | 2003 | Unclear | NR | NR | Yes | NR | Stuart | No | No | NR | NR | Poor
Taylor | 2006 | Yes | NR | No; significantly more single patients in one group (11% vs 0, p=0.01) | Yes | NR | Taylor | N/A | No | No; 7/121 (6%) | No; TC=4/62 (6.4%), TM=3/59 (5.1%) | Fair
Tsang | 2001 | Unclear | NR | No; duration of illness significantly greater for one group | No | No | Tsang | No | No | No=1/20 (5%) | No: Group 1=0, Group 2=1/10 (10%) | Fair
Turnin | 1992 | Unclear | No | Yes | Yes | Unclear | Turnin | No | No | Yes; (16% in group A and 1.9% in group B in study 1) | Yes | Fair
Williamson | 2006 | Yes | No | Yes | Yes | No | Williamson | No | No | Yes; (24% in control and 36% in treatment) | Yes | Good
Winzelberg | 2003 | Unclear | Unclear/NR | Yes | Yes | Unclear/NR | Winzelberg | No | No | Yes; 14/72 (19.4%) | No; intervention=8/36 (22.2%), WLC=6/36 (16.7%) | Fair
Wylie- Rosett | 2001 | Yes | Unclear | Yes | Yes | Unclear | Wylie- Rosett | No | No | Unclear | NR | Fair
Zimmerman | 2004 | Unclear | No | NR | Yes | Unclear | Zimmerman | No | No | No | No | Fair

### Randomized Controlled Trial References

Andersson G, Bergstrom J, Hollandare F, Carlbring P, Kaldo V, Ekselius L. Internet-based self-help for depression: randomised controlled trial. British Journal of Psychiatry. 2005;187:456-461. [pmid: 16260822].
Andersson G, Carlbring P, Holmstrom A, Sparthan E, Furmark T, Nilsson-Ihrfelt E, et al. Internet-based self-help with therapist feedback and in vivo group exposure for social phobia: a randomized controlled trial. Journal of consulting and clinical psychology. 2006;74(4):677-686. [pmid: 16881775].
Andersson G, Lundstrom P, Strom L. Internet-based treatment of headache: does telephone contact add anything?. Headache. 2003;43(4):353-361. [pmid: 12656706].
Andrade A. HIV adherence strategies take a high-tech route. AIDS Alert. 2001;16(8):97-98. [pmid: 11547705].
Andrade ASA, McGruder HF, Wu AW, Celano SA, Skolasky RL Jr, Selnes OA, et al. A programmable prompting device improves adherence to highly active antiretroviral therapy in HIV-infected subjects with memory impairment. Clinical Infectious Diseases. 2005;41(6):875-882. [pmid: 16107989].
Araki I, Hashimoto H, Kono K, Matsuki H, Yano E. Controlled trial of worksite health education through face-to-face counseling vs. e-mail on drinking behavior modification. Journal of Occupational Health. 2006;48(4):239-245. [pmid: 16902267].
Armstrong K, Weber B, Ubel PA, Peters N, Holmes J, Schwartz JS. Individualized survival curves improve satisfaction with cancer risk management decisions in women with BRCA1/2 mutations. Journal of Clinical Oncology. 2005;23(36):9319-9328. [pmid: 16361631].
Artinian NT, Harden JK, Kronenberg MW, Vander Wal JS, Daher E, Stephens Q, et al. Pilot study of a Web-based compliance monitoring device for patients with congestive heart failure. Heart & Lung. 2003;32(4):226-233. [pmid: 12891162].
Bachofen M, Nakagawa A, Marks IM, Park JM, Greist JH, Baer L, et al. Home self-assessment and self-treatment of obsessive-compulsive disorder using a manual and a computer-conducted telephone interview: replication of a UK-US study. Journal of Clinical Psychiatry. 1999;60(8):545-549. [pmid: 10485637].
Barnason S, Zimmerman L, Nieveen J, Hertzog M. Impact of a telehealth intervention to augment home health care on functional and recovery outcomes of elderly patients undergoing coronary artery bypass grafting. Heart & Lung. 2006;35(4):225-233. [pmid: 16863894].
Barnason S, Zimmerman L, Nieveen J, Schmaderer M, Carranza B, Reilly S. Impact of a home communication intervention for coronary artery bypass graft patients with ischemic heart failure on self-efficacy, coronary disease risk factor modification, and functioning. Heart & Lung. 2003;32(3):147-158. [pmid: 12827099].
Barrera M Jr, Glasgow RE, McKay HG, Boles SM, Feil EG. Do Internet-based support interventions change perceptions of social support?: An experimental trial of approaches for supporting diabetes self-management. American Journal of Community Psychology. 2002;30(5):637-654. [pmid: 12188054].
Block G, Wakimoto P, Metz D, Fujii ML, Feldman N, Mandel R, et al. A randomized trial of the Little by Little CD-ROM: demonstrated effectiveness in increasing fruit and vegetable intake in a low-income population. Preventing Chronic Disease. 2004;1(3):A08.
Carlbring P, Gunnarsdottir M, Hedensjo L, Andersson G, Ekselius L, Furmark T. Treatment of social phobia: randomised trial of internet-delivered cognitive-behavioural therapy with telephone support. British Journal of Psychiatry. 2007;190:123-128. [pmid: 17267928].
Cawsey AJ, Jones RB, Pearson J. The evaluation of a personalised health information system for patients with cancer. User Modeling and User-Adapted Interaction. 2000;10(1):47-72.
Chan DS, Callahan CW, Sheets SJ, Moreno CN, Malone FJ. An Internet-based store-and-forward video home telehealth system for improving asthma outcomes in children. American Journal of Health-System Pharmacy. 2003;60(19):1976-1981. [pmid: 14531243].
Chen H, Yeh M, Chao Y. Comparing effects of auricular acupressure with and without an Internet-assisted program on smoking cessation and self-efficacy of adolescents. Journal of Alternative and Complementary Medicine. 2006;12(2):147-152.
Cho JH, Chang SA, Kwon HS, Choi YH, Ko SH, Moon SD, et al. Long-term effect of the Internet-based glucose monitoring system on HbA1c reduction and glucose stability: a 30-month follow-up study for diabetes management with a ubiquitous medical care system. Diabetes Care. 2006;29(12):2625-2631. [pmid: 17130195].
Christensen H, Griffiths KM, Jorm AF. Delivering interventions for depression by using the internet: randomised controlled trial. BMJ. 2004;328(7434):265. [pmid: 14742346].
Cruz-Correia R, Fonseca J, Lima L, Araujo L, Delgado L, Castel-Branco MG, et al. Web-based or paper-based self-management tools for asthma—patients' opinions and quality of data in a randomized crossover study. Studies in Health Technology & Informatics. 2007;127:178-189. [pmid: 17901611].
Estabrooks PA, Nelson CC, Xu S, King D, Bayliss EA, Gaglio B, et al. The frequency and behavioral outcomes of goal choices in the self-management of diabetes. Diabetes Educator. 2005;31(3):391-400. [pmid: 15919639].
Franklin VL, Waller A, Pagliari C, Greene SA. A randomized controlled trial of Sweet Talk, a text-messaging system to support young people with diabetes. Diabetic Medicine. 2006;23(12):1332-1338. [pmid: 17116184].
Frenn M, Malin S, Brown RL, Greer Y, Fox J, Greer J, et al. Changing the tide: an Internet/video exercise and low-fat diet intervention with middle-school students. Applied nursing research : ANR. 2005;18(1):13-21. [pmid: 15812731].
Gega L, Marks I, Mataix-Cols D. Computer-aided CBT self-help for anxiety and depressive disorders: experience of a London clinic and future directions. Journal of Clinical Psychology. 2004;60(2):147-157. [pmid: 14724922].
Glasgow RE, Boles SM, McKay HG, Feil EG, Barrera M Jr. The D-Net diabetes self-management program: long-term implementation, outcomes, and generalization results. Preventive Medicine. 2003;36(4):410-419. [pmid: 12649049].
Glasgow RE, Toobert DJ. Brief, computer-assisted diabetes dietary self-management counseling: effects on behavior, physiologic outcomes, and quality of life. Medical Care. 2000;38(11):1062-1073. [pmid: 11078048].
Green B, et al. Effectiveness of Home Blood Pressure Monitoring, Web Communication, and Pharmacist Care on Hypertension Control. JAMA. 2008;299(24):2857-2867. [pmid: 18577730].
Guendelman S, Meade K, Benson M, Chen YQ, Samuels S. Improving asthma outcomes and self-management behaviors of inner-city children: a randomized trial of the Health Buddy interactive device and an asthma diary. Archives of Pediatrics & Adolescent Medicine. 2002;156(2):114-120. [pmid: 11814370].
Gustafson DH, Hawkins R, Boberg E, Pingree S, Serlin RE, Graziano F, et al. Impact of a patient-centered, computer-based health information/support system. American Journal of Preventive Medicine. 1999;16(1):1-9.
Gustafson, D. H., Hawkins, R. P., Boberg, E. W., Bricker, E., Pingree, S., & Chan, C. L. (1994). The use and impact of a computer-based support system for people living with AIDS and HIV infection. Proceedings - the Annual Symposium on Computer Applications in Medical Care, 604–608.
Gustafson DH, Hawkins RP, Boberg EW, McTavish F, Owens B, Wise M, et al. CHESS: ten years of research and development in consumer health informatics for broad populations, including the underserved. Medinfo. 2001;10(Pt 2):1459-1563.
Gustafson DH, Hawkins R, Pingree S, McTavish F, Arora NK, Mendenhall J, et al. Effect of computer support on younger women with breast cancer. Journal of General Internal Medicine. 2001;16(7):435-445. [pmid: 11520380].
Holman RR, Smale AD, Pemberton E, Riefflin A, Nealon JL. Randomized controlled pilot trial of a hand-held patient-oriented, insulin regimen optimizer. Medical Informatics. 1996;21(4):317-326. [pmid: 9179835].
Jan RL, Wang JY, Huang MC, Tseng SM, Su HJ, Liu LF. An internet-based interactive telemonitoring system for improving childhood asthma outcomes in Taiwan. Telemedicine Journal & E-Health. 2007;13(3):257-268. [pmid: 17603828].
Japuntich SJ, Zehner ME, Smith SS, Jorenby DE, Valdez JA, Fiore MC, et al. Smoking cessation via the internet: a randomized clinical trial of an internet intervention as adjuvant treatment in a smoking cessation intervention. Nicotine & Tobacco Research. 2006;8(Suppl 1):S59-67. [pmid: 17491172].
Jones R, Pearson J, McGregor S, Cawsey AJ, Barrett A, Craig N, et al. Randomised trial of personalised computer based information for cancer patients. BMJ. 1999;319(7219):1241-1247. [pmid: 10550090].
Jones RB, Atkinson JM, Coia DA, Paterson L, Morton AR, McKenna K, et al. Randomised trial of personalised computer based information for patients with schizophrenia.[erratum appears in BMJ 2001 May 5;322(7294):1103]. BMJ. 2001;322(7290):835-840. [pmid: 11290639].
Joseph CLM, Peterson E, Havstad S, Johnson CC, Hoerauf S, Stringer S, et al. A web-based, tailored asthma management program for urban African-American high school students. American Journal of Respiratory & Critical Care Medicine. 2007;175(9):888-895. [pmid: 17290041].
Kashem A, Droogan MT, Santamore WP, Wald JW, Marble JF, Cross RC, et al. Web-based Internet telemedicine management of patients with heart failure. Telemedicine journal and e-health : the official journal of the American Telemedicine Association. 2006;12(4):439-447. [pmid: 16942416].
Kenwright M, Marks I, Graham C, Franses A, Mataix-Cols D. Brief scheduled phone support from a clinician to enhance computer-aided self-help for obsessive-compulsive disorder: randomized controlled trial. Journal of Clinical Psychology. 2005;61(12):1499-1508. [pmid: 16173084].
Kenwright M, Marks IM. Computer-aided self-help for phobia/panic via internet at home: a pilot study. British Journal of Psychiatry. 2004;184:448-449. [pmid: 15123511].
Kim C, Kang D. Utility of a Web-based intervention for individuals with type 2 diabetes: the impact on physical activity levels and glycemic control. CIN: Computers, Informatics, Nursing. 2006a;24(6):337-345.
Kim H. A randomized controlled trial of a nurse short-message service by cellular phone for people with diabetes. International Journal of Nursing Studies. 2007;44(5):687-692. [pmid: 16618486].
Kosma M, Cardinal BJ, McCubbin JA. A pilot study of a web-based physical activity motivational program for adults with physical disabilities. Disability and rehabilitation. 2005;27(23):1435-1442. [pmid: 16418058].
Kressig RW, Echt KV. Exercise prescribing: computer application in older adults. Gerontologist. 2002;42(2):273-277. [pmid: 11914468].
Kwon HS, Cho JH, Kim HS, Song BR, Ko SH, Lee JM, et al. Establishment of blood glucose monitoring system using the internet. Diabetes Care. 2004;27(2):478-483. [pmid: 14747232].
LaFramboise LM, Todero CM, Zimmerman L, Agrawal S. Comparison of Health Buddy with traditional approaches to heart failure management. Family and Community Health. 2003;26(4):275-288. [pmid: 14528134].
Lahm EA. Software That Engages Young Children with Disabilities: A Study of Design Features. [Journal Articles Reports - Research]. Focus on Autism and Other Developmental Disabilities. 1996;11(2):115-124.
Lee TI, Yeh YT, Liu CT, Chen PL. Development and evaluation of a patient-oriented education system for diabetes management. International Journal of Medical Informatics. 2007;76(9):655-663. [pmid: 16815741].
Leu MG, Norris TE, Hummel J, Isaac M, Brogan MW. A randomized, controlled trial of an automated wireless messaging system for diabetes. Diabetes Technology & Therapeutics. 2005;7(5):710-718. discussion 719–720. [pmid: 16241873].
Levetan CS, Dawn KR, Robbins DC, Ratner RE. Impact of computer-generated personalized goals on HbA(1c). Diabetes Care. 2002;25(1):2-8. [pmid: 11772893].
Lorig KR, Ritter PL, Laurent DD, Plant K. Internet-based chronic disease self-management: a randomized trial. Medical Care. 2006;44(11):964-971. [pmid: 17063127].
McKay HG, King D, Eakin EG, Seeley JR, Glasgow RE. The diabetes network internet-based physical activity intervention: a randomized pilot study. Diabetes Care. 2001;24(8):1328-1334. [pmid: 11473065].
McMahon GT, Gomes HE, Hickson Hohne S, Hu TM, Levine BA, Conlin PR. Web-based care management in patients with poorly controlled diabetes. Diabetes care. 2005;28(7):1624-1629. [pmid: 15983311].
McPherson AC, Glazebrook C, Forster D, James C, Smyth A. A randomized, controlled trial of an interactive educational computer package for children with asthma. Pediatrics. 2006;117(4):1046-1054. [pmid: 16585298].
Meigs JB, Cagliero E, Dubey A, Murphy-Sheehy P, Gildesgame C, Chueh H, et al. A controlled trial of web-based diabetes disease management: the MGH diabetes primary care improvement project. Diabetes care. 2003;26(3):750-757. [pmid: 12610033].
Noel HC, Vogel DC, Erdos JJ, Cornwall D, Levin F. Home telehealth reduces healthcare costs. Telemedicine journal and e-health : the official journal of the American Telemedicine Association. 2004;10(2):170-183. [pmid: 15319047].
Owen JE, Klapow JC, Roth DL, Shuster JL Jr, Bellis J, Meredith R, et al. Randomized pilot of a self-guided internet coping group for women with early-stage breast cancer. Annals of Behavioral Medicine. 2005;30(1):54-64. [pmid: 16097906].
Pike KJ, Rabius V, McAlister A, Geiger A. American Cancer Society's QuitLink: randomized trial of Internet assistance. Nicotine & Tobacco Research. 2007;9(3):415-420. [pmid: 17365773].
Rami B, Popow C, Horn W, Waldhoer T, Schober E. Telemedical support to improve glycemic control in adolescents with type 1 diabetes mellitus. European Journal of Pediatrics. 2006;165(10):701-705. [pmid: 16670859].
Reid RD, Pipe AL, Quinlan B, Oda J. Interactive voice response telephony to promote smoking cessation in patients with heart disease: a pilot study. Patient Education & Counseling. 2007;66(3):319-326. [pmid: 17336026].
Robertson L, Smith M, Castle D, Tannenbaum D. Using the Internet to enhance the treatment of depression. Australasian Psychiatry. 2006;14(4):413-417. [pmid: 17116083].
Robertson L, Smith M, Tannenbaum D. Case management and adherence to an online disease management system. Journal of Telemedicine & Telecare. 2005;11(Suppl 2):S73-75. [pmid: 16375805].
Rodgers A, Corbett T, Bramley D, Riddell T, Wills M, Lin RB, et al. Do u smoke after txt? Results of a randomised trial of smoking cessation using mobile phone text messaging. Tobacco Control. 2005;14(4):255-261. [pmid: 16046689].
Rogers MAM, Small D, Buchan DA, Butch CA, Stewart CM, Krenzer BE, et al. Home monitoring service improves mean arterial pressure in patients with essential hypertension: a randomized, controlled trial. Annals of Internal Medicine. 2001;134(11):1024-1032. I1042. [pmid: 11388815].
Ross SE, Moore LA, Earnest MA, Wittevrongel L, Lin CT. Providing a web-based online medical record with electronic communication capabilities to patients with congestive heart failure: randomized trial. Journal of Medical Internet Research. 2004;6(2):e12. [pmid: 15249261].
Ruland CM, White T, Stevens M, Fanciullo G, Khilani SM. Effects of a computerized system to support shared decision making in symptom management of cancer patients: preliminary results. Journal of the American Medical Informatics Association. 2003;10(6):573-579. [pmid: 12925545].
Sciamanna CN, Harrold LR, Manocchia M, Walker NJ, Mui S. The effect of web-based, personalized, osteoarthritis quality improvement feedback on patient satisfaction with osteoarthritis care. American Journal of Medical Quality. 2005;20(3):127-137. [pmid: 15951518].
Shapiro JR, Reba-Harrelson L, Dymek-Valentine M, Woolson SL, Hamer RM, Bulik CM. Feasibility and acceptability of CD-ROM-based cognitive-behavioural treatment for binge-eating disorder. European Eating Disorders Review. 2007;15(3):175-184. [pmid: 17676687].
Shegog R, Bartholomew LK, Parcel GS, Sockrider MM, Masse L, Abramson SL. Impact of a computer-assisted education program on factors related to asthma self-management behavior. Journal of the American Medical Informatics Association. 2001;8(1):49-61. [pmid: 11141512].
Smith L, Weinert C. Telecommunication support for rural women with diabetes. Diabetes Educator. 2000;26(4):645-655. [pmid: 11140073].
Southard BH, Southard DR, Nuckolls J. Clinical trial of an Internet-based case management system for secondary prevention of heart disease. Journal of Cardiopulmonary Rehabilitation. 2003;23(5):341-348. [pmid: 14512778].
Strecher VJ, Shiffman S, West R. Moderators and mediators of a web-based computer-tailored smoking cessation program among nicotine patch users. Nicotine & Tobacco Research. 2006;8(Suppl 1):S95-101. [pmid: 17491176].
Stuart GW, Laraia MT, Ornstein SM, Nietert PJ. An interactive voice response system to enhance antidepressant medication compliance. Topics in Health Information Management. 2003;24(1):15-20. [pmid: 12674391].
Taylor Y, Eliasson A, Andrada T, Kristo D, Howard R. The role of telemedicine in CPAP compliance for patients with obstructive sleep apnea syndrome. Sleep & Breathing. 2006;10(3):132-138. [pmid: 16565867].
Tsang MW, Mok M, Kam G, Jung M, Tang A, Chan U, et al. Improvement in diabetes control with a monitoring system based on a hand-held, touch-screen electronic diary. Journal of Telemedicine & Telecare. 2001;7(1):47-50.
Turnin MC, Beddok RH, Clottes JP, Martini PF, Abadie RG, Buisson JC, et al. Telematic expert system Diabeto. New tool for diet self-monitoring for diabetic patients. Diabetes Care. 1992;15(2):204-212. [pmid: 1547677].
Williamson DA, Walden HM, White MA, York-Crowe E, Newton RL Jr, Alfonso A, et al. Two-Year Internet-Based Randomized Controlled Trial for Weight Loss in African-American Girls. Obesity. 2006;14(7):1231-1243. [pmid: 16899804].
Winzelberg AJ, Classen C, Alpers GW, Roberts H, Koopman C, Adams RE, et al. Evaluation of an internet support group for women with primary breast cancer. Cancer. 2003;97(5):1164-1173. [pmid: 12599221].
Wylie-Rosett J, Swencionis C, Ginsberg M, Cimino C, Wassertheil-Smoller S, Caban A, et al. Computerized weight loss intervention optimizes staff time: the clinical and cost results of a controlled clinical trial conducted in a managed care setting. Journal of the American Dietetic Association. 2001;101(10):1155-1162. quiz 1163–1154. [pmid: 11678486].
Zimmerman L, Barnason S, Nieveen J, Schmaderer M. Symptom management intervention in elderly coronary artery bypass graft patients. Outcomes Management. 2004;8(1):5-12. [pmid: 14740578].

## Cohort Studies

Author | Year | Sufficient description of the groups? | Intervention/ treatment reliably ascertained? | Groups comparable? | Adequate adjustment of confounding factors? | Groups assembled at a similar point? | Author | Blind to exposure status? | Follow-up long enough? | High withdrawal/attrition rate? | Rate differential by group? | Quality Rating
Alibisser | 2001 | No | Unclear; usage metrics NR | Unclear; comparability of baseline characteristics NR, but possible differences in baseline HbA1c levels (9.5 vs 8.5) | No | Unclear | Alibisser | Unclear | Yes; 1 year | Unclear | Unclear | Poor
An | 2006 | Yes | No | Yes for measured characteristics; unclear for unmeasured factors of motivation and readiness to quit | No | Unclear | An | Unclear | Unclear | No; 32/304 (10.5%) | Yes; for abstinance survey; beta=22/47 (46.8%), RealU=10/257 (3.9%) | Poor
Gerber | 2007 | Yes | Yes | NA | NA | Yes | Gerber | Unclear | Yes | No | NA | Fair
Kim | 2006b | Yes | Yes | Baseline characteristics provided for group; pre-post test one sample | NA | NA | Kim | NA | No; 12 weeks | 44 started;33 completed; 27% did not complete (n=12) | NA | Fair
McClure | 2006 | Yes | Yes | No; newsletter recruitees were more likely to be female, caucasian, and older | No | Unclear | McClure | Unclear | Unclear; NR | N/A; outcome measure is response rate | N/A; outcome measure is response rate | Fair
McTavish | 1995 | Yes | Yes | NA | NA | Yes | McTavish | Unclear | Yes | No | NA | Fair
Nakagawa | 2000 | Yes | Yes | Unclear | No | Yes | Nakagawa | No | Unclear; 3 weeks | Yes; 52.4% | N/A; historical controls selected, in part, based on availability of case notes and outcome data | Poor
Nguyen | 2005 | Yes | Yes | Yes | NA | Unclear | Nguyen | Unclear | Unclear; 3 months | Yes; 7/23 (30.4%) | Yes; booster group=5/12 (41.7%), primary=2/11 (18.2%) | Poor
Runge | 2006 | Yes | No; 45.2% of ITT population did not use the intervention | No; significantly more males in control group (79.2% vs 54.7% vs 65.9%) | Unclear | Yes | Runge | NR | Yes; 12 months | Yes; 34.8% | Yes; control=20%, SPMP=63%, SPMP plus IEP=18.5% | Poor
Safren | 2003 | No | No | NR | NR | NR | Safren | NR | Yes; 12 weeks | NR | NR | Poor
Shaw | 2007 | Yes | Yes | Yes | Yes | Yes | Shaw | Yes | Unclear; 4 months | Unclear/NR | Unclear; NR | Fair
Van den Brink | 2005 | Yes | Unclear | NA | NA | Yes | Van den Brink | Unclear | Yes | No | No | Fair
Van der Meer | 2007 | Yes | Yes | Yes | NA | No | Van der Meer | Unclear | Yes | No | NA | Fair
Weinert | 2005 | Yes | Unclear; adherence NR | Unclear; baseline characteristics reported only as combined across groups | No adjustments made | Unclear | Weinert | NR | Yes; 18 months | NR | NR | Poor

### Cohort Study References

Albisser AM, Harris RI, Albisser JB, Sperlich M. The impact of initiatives in education, self-management training, and computer-assisted self-care on outcomes in diabetes disease management. Diabetes Technology & Therapeutics. 2001;3(4):571-579. [pmid: 11911169].
An LC, Perry CL, Lein EB, Klatt C, Farley DM, Bliss RL, et al. Strategies for increasing adherence to an online smoking cessation intervention for college students. Nicotine & Tobacco Research. 2006;8(Suppl 1):S7-12. [pmid: 17491165].
Gerber BS, Solomon MC, Shaffer TL, Quinn MT, Lipton RB. Evaluation of an internet diabetes self-management training program for adolescents and young adults. Diabetes Technology & Therapeutics. 2007;9(1):60-67. [pmid: 17316099].
Kim H, Kim N, Ahn S. Impact of a nurse short message service intervention for patients with diabetes. Journal of Nursing Care Quality. 2006b;21(3):266-271.
McClure JB, Greene SM, Wiese C, Johnson KE, Alexander G, Strecher V. Interest in an online smoking cessation program and effective recruitment strategies: results from Project Quit. Journal of Medical Internet Research. 2006;8(3):e14. [pmid: 16954124].
McTavish, F. M., Gustafson, D. H., Owens, B. H., Wise, M., Taylor, J. O., Apantaku, F. M., et al. (1994). CHESS: An interactive computer system for women with breast cancer piloted with an under-served population. Proceedings - the Annual Symposium on Computer Applications in Medical Care, 599–603.
Nakagawa A, Marks IM, Park JM, Bachofen M, Baer L, Dottl SL, et al. Self-treatment of obsessive-compulsive disorder guided by manual and computer-conducted telephone interview. Journal of Telemedicine & Telecare. 2000;6(1):22-26. [pmid: 10824386].
Nguyen HQ, Carrieri-Kohlman V, Rankin SH, Slaughter R, Stulbarg MS. Is Internet-based support for dyspnea self-management in patients with chronic obstructive pulmonary disease possible? Results of a pilot study. Heart & Lung. 2005;34(1):51-62. [pmid: 15647734].
Runge C, Lecheler J, Horn M, Tews JT, Schaefer M. Outcomes of a Web-based patient education program for asthmatic children and adolescents. Chest. 2006;129(3):581-593. [pmid: 16537855].
Safren SA, Hendriksen ES, Desousa N, Boswell SL, Mayer KH. Use of an on-line pager system to increase adherence to antiretroviral medications. AIDS Care. 2003;15(6):787-793. [pmid: 14617500].
Shaw BR, Han JY, Baker T, Witherly J, Hawkins RP, McTavish F, et al. How women with breast cancer learn using interactive cancer communication systems. Health Education Research. 2007;22(1):108-119. [pmid: 16829544].
van den Brink JL, Moorman PW, de Boer MF, Pruyn JFA, Verwoerd CDA, van Bemmel JH. Involving the patient: a prospective study on use, appreciation and effectiveness of an information system in head and neck cancer care. International Journal of Medical Informatics. 2005;74(10):839-849. [pmid: 16043392].
van der Meer V, van Stel HF, Detmar SB, Otten W, Sterk PJ, Sont JK. Internet-based self-management offers an opportunity to achieve better asthma control in adolescents. Chest. 2007;132(1):112-119. [pmid: 17400674].
Weinert C, Cudney S, Winters C. Social support in cyberspace: the next generation. CIN: Computers, Informatics, Nursing. 2005;23(1):7-15.

## Case Series Studies

Author | Year | Representative sample? | Inclusion explicit? | Did individuals enter survey at a similar point? | Follow-up long enough? | Outcomes assessed with objective criteria? | Author | Quality Rating
Brennan | 2001 | Unclear; selection methods NR | NR | Unclear; medical history NR | No; 1 week | Yes | Brennan | Poor
Cavan | 2003 | Unclear; how patients were selected | No;patients described as having Type I Diabetes | No; duration of diabetes ranged from 3 to 29 years | Unclear; 6 months | No | Cavan | Poor
Cross | 2007 | Yes | Yes | No; average duration of disease was 5.8, with a SD of 5.1 | Yes; 6 months | Partly; both laboratory and subjective measures used | Cross | Fair
Durso | 2003 | No; investigator selected | No | No; 40% took ≥ 9 medications/day, 30% managed with insulin, others treated with oral antidiabetics | Unclear; 3 months | Yes | Durso | Poor
Ewald | 2006 | Yes | Yes | No; duration of hypertension ranged from 0 to 23 years | Yes; 12 weeks | Yes | Ewald | Fair
Ferrer-Roca | 2004 | Unclear | Yes | Unclear | Yes | Yes | Ferrer-Roca | Poor
Finkelstein | 1996 | Yes | Yes | Yes | Yes; 12 months | Yes | Finkelstein | Good
Gerber | 2007 | No | Yes | No | Yes; 6 months | Yes | Gerber | Fair
Gerbert | 2003 | No | Yes | NR | Yes; single administration | Partly | Gerbert | Fair
Gustafson | 1998 | No | Yes | Yes | Unclear; 10 weeks | Yes | Gustafson | Fair
Labiris | 2004 | Unclear; recruitment methods NR | No | Unclear; only age and gender reported | Yes; 8 years | Unclear; used "predetermined questionnaires, in Likert-scale forms | Labiris | Poor
Lieberman | 2003 | No; self-selected volunteers | Yes | Unclear | Yes | Yes | Lieberman | Poor
Ma | 2006 | No | No | Unclear; NR | Yes; 3 months | Yes | Ma | Fair
McDaniel | 2002 | Unclear if selection was consecutive | Yes | No | No; 1 week | Yes | McDaniel | Fair
Nguyen | 2003 | Unclear; selection criteria NR | N | Unclear | Unclear; 3 months | Party | Nguyen | Poor
Piette | 1997 | Yes | Yes | No | Unclear; 4 weeks | Yes | Piette | Fair
Skeels | 2006 | Unclear | No | Unclear/NR | No; single session | Yes | Skeels | Poor
Stinson | 2006 | Yes | Yes | N/A | No; 1 session | Yes | Stinson | Fair
van den Berg | 2007 | No | Yes | No | Yes; 12 months | Party: Yes for technology usage, No for satisfaction | van den Berg | Fair
van der Meer | 2007 | Yes | Yes | N/A | No; 1 month | Yes | van der Meer | Fair
Wilkie | 2001 | No | Yes | Unclear | Unclear; 1 month | Yes | Wilkie | Fair
Woodruff | 2001 | No | Yes | Unclear | Unclear; 3 months | No | Woodruff | Poor
Zabinski | 2001 | Unclear | Yes | Unclear | Unclear; 10 weeks | Yes | Zabinski | Fair

### Case Series Study References

Brennan PF, Moore SM, Bjornsdottir G, Jones J, Visovsky C, Rogers M. HeartCare: an Internet-based information and support system for patient home recovery after coronary artery bypass graft (CABG) surgery. Journal of Advanced Nursing. 2001;35(5):699-708. [pmid: 11529972].
Cavan DA, Everett J, Plougmann S, Hejlesen OK. Use of the Internet to optimize self-management of type 1 diabetes: preliminary experience with DiasNet. Journal of Telemedicine & Telecare. 2003;9(Suppl 1):S50-52. [pmid: 12952722].
Cross RK, Finkelstein J. Feasibility and acceptance of a home telemanagement system in patients with inflammatory bowel disease: a 6-month pilot study. Digestive Diseases & Sciences. 2007;52(2):357-364. [pmid: 17211702].
Durso SC, Wendel I, Letzt AM, Lefkowitz J, Kaseman DF, Seifert RF. Older adults using cellular telephones for diabetes management: a pilot study. MEDSURG Nursing. 2003;12(5):313-317. [pmid: 14608688].
Ewald S, vor dem Esche J, Uen S, Neikes F, Vetter H, Mengden T. Relationship between the frequency of blood pressure self-measurement and blood pressure reduction with antihypertensive therapy : results of the OLMETEL (OLMEsartan TELemonitoring blood pressure) study. Clinical Drug Investigation. 2006;26(8):439-446. [pmid: 17163276].
Ferrer-Roca O, Cardenas A, Diaz-Cardama A, Pulido P. Mobile phone text messaging in the management of diabetes. Journal of Telemedicine & Telecare. 2004a;10(5):282-285.
Finkelstein SM, Snyder M, Edin-Stibbe C, Chlan L, Prasad B, Dutta P, et al. Monitoring progress after lung transplantation from home-patient adherence. Journal of Medical Engineering & Technology. 1996;20(6):203-210. [pmid: 9029392].
Gerber BS, Solomon MC, Shaffer TL, Quinn MT, Lipton RB. Evaluation of an internet diabetes self-management training program for adolescents and young adults. Diabetes Technology & Therapeutics. 2007;9(1):60-67. [pmid: 17316099].
Gerbert B, Berg-Smith S, Mancuso M, Caspers N, McPhee S, Null D, et al. Using innovative video doctor technology in primary care to deliver brief smoking and alcohol intervention. Health Promotion Practice. 2003;4(3):249-261. [pmid: 14610995].
Gustafson DH, McTavish F, Hawkins R, Pingree S, Arora N, Mendenhall J, et al. Computer support for elderly women with breast cancer. JAMA. 1998;280(15):1305. [pmid: 9794300].
Labiris G, Papadopoulis G, Lentaris G, Kafentzis M, Krakakis A. Internet based counseling to remote orthopedic patients. Acta Orthopaedica Scandinavica. 2004;75(3):366-367. [pmid: 15260433].
Lieberman DZ. Determinants of satisfaction with an automated alcohol evaluation program. CyberPsychology & Behavior. 2003;6(6):677-682. [pmid: 14756935].
Ma C, Warren J, Phillips P, Stanek J. Empowering patients with essential information and communication support in the context of diabetes. International Journal of Medical Informatics. 2006;75(8):577-596. [pmid: 16213783].
McDaniel, A. M., Hutchison, S., Casper, G. R., Ford, R. T., Stratton, R., & Rembusch, M. (2002). Usability testing and outcomes of an interactive computer program to promote smoking cessation in low income women. Proceedings / AMIA, Annual Symposium., 509–513.
Nguyen, H. Q., Carrieri-Kohlman, V., Rankin, S. A., Slaughter, R., & Stulbarg, M. S. (2003). Pilot study of an online dyspnea self-management program for COPD. AMIA, Annual Symposium Proceedings/AMIA Symposium., 951.
Piette JD, Mah CA. The feasibility of automated voice messaging as an adjunct to diabetes outpatient care. Diabetes Care. 1997;20(1):15-21. [pmid: 9028687].
Skeels, M. M., Kurth, A., Clausen, M., Severynen, A., & Garcia-Smith, H. (2006). CARE+ user study: usability and attitudes towards a tablet pc computer counseling tool for HIV+ men and women. AMIA, Annual Symposium Proceedings/AMIA Symposium., 729–733.
Stinson JN, Petroz GC, Tait G, Feldman BM, Streiner D, McGrath PJ, et al. e-Ouch: usability testing of an electronic chronic pain diary for adolescents with arthritis. Clinical Journal of Pain. 2006;22(3):295-305. [pmid: 16514331].
van den Berg MH, Ronday HK, Peeters AJ, Voogt-van der Harst EM, Munneke M, Breedveld FC, et al. Engagement and satisfaction with an Internet-based physical activity intervention in patients with rheumatoid arthritis. Rheumatology. 2007;46(3):545-552. [pmid: 17043050].
van der Meer V, van Stel HF, Detmar SB, Otten W, Sterk PJ, Sont JK. Internet-based self-management offers an opportunity to achieve better asthma control in adolescents. Chest. 2007;132(1):112-119. [pmid: 17400674].
Wilkie DJ, Huang HY, Berry DL, Schwartz A, Lin YC, Ko NY, et al. Cancer symptom control: feasibility of a tailored, interactive computerized program for patients. Family & Community Health. 2001;24(3):48-62. [pmid: 11563944].
Woodruff SI, Edwards CC, Conway TL, Elliott SP. Pilot test of an Internet virtual world chat room for rural teen smokers. Journal of Adolescent Health. 2001;29(4):239-243. [pmid: 11587907].
Zabinski MF, Wilfley DE, Pung MA, Winzelberg AJ, Eldredge K, Taylor CB. An interactive internet-based intervention for women at risk of eating disorders: a pilot study. International Journal of Eating Disorders. 2001;30(2):129-137. [pmid: 11449446].

## Abbreviations for all Quality Assessments

BMI = body mass index

CIT = conventional insulin therapy

CTRL = control

IIT = individualized insulin therapy

ITT = Intention to treat analysis

IVR = interactive voice response

JAMA = Journal of the American Medical Association

NA=not applicable

NR=not reported

NS=not significant

RA = Rheumatoid Arthritis

SD = standard deviation

SDS = standard deviation scores

SI = special intervention

UC = usual care

WLC = weight list control