# Appendix H. Data Abstraction Table with References

| | | | | | | | | | | Patient Characteristics* | | | | | | | | | | | | | | | Intervention* | | | | | | | | Outcomes
Author | Year | Patient Recruitment Setting | Clinical Practice Setting | Patient Technology Setting | Study design | N | Years of Study | Length of follow-up (months) | Inclusion Criteria | Exclusion Criteria | Elderly | Underserved | Chronic Illness | Disability/Impairment | Gender (% Male) | Age (years) | Ethnicity | Income (US$) | Education | Urban / Rural / Frontier | Other | Health Insurance Status | Literacy | Language(s) | Health Beliefs | Intervention Name | Intervention Described | Intervention Groups | Type of Device* | Functions* | Staff Training | Subject Training | co-interventions | Physiologic | Health Service Utilization | Health Care Costs | Knowledge | Use of Technology | Usability | HIT Satisfaction | Health Satisfaction | Self-efficacy | Health Behavior | Quality of Life | Support | Withdrawals | Adverse Effects | Other
Albisser | 2001 | Mixed model HMO with a membership of 275,000 | Primary and/or subspecialty care physicians all generally in a mixed model HMO with a membership of 275,000 | Homes | Quasi-experimental, longitudinal observation study design | N = 978 E-alone: 151 E+SMT: 589 E+caSC: 238) DCCT initiative: 101 | NR | 12 months | *Enrollment in the HMO-sponsored disease management programs. | NR | NR | NR | DIABETES | NR | NR | Mean Age: 58 Range: 19–81 | NR | NR | NR | NR | Male body weight at baseline: 63–136kg Female body weight at baseline: 56–131kg. | NR | NR | NR | NR | NR | Each patient received and continued to receive standardized diabetes education. The second initiative sought to augment the education component by adding ongoing, self-management training. The third initiative added computer-assisted self-care to the same education component. | Group 1: (E-alone) Education alone Group 2: (E+SMT) education supplemented with self-management training Group 3: (E+caSC) education supplemented with computer-assisted self-care Group 4: (Control) (DCCT initiative) Glycolated Hemoglobin A1c values in Diabetes patients. | Touch-tone telephone (recorded to a computer) | To record data as reported by patients, pass this information through an algorithm, and pass intervention instructions to the patient. | One case worker was dedicated to the computer-assisted self-care initiative, which was under the direction of an endocrinologist to whole the difficult-to-manage patients were referred. | Received standardized diabetes education | NR | HbA1c Group 2 (E+SMT). Significant improvement from baseline (8.8 ± 1.5%) to 8.7 ± 1.4% at 3 months (p < 0.01). Significant improvement from 3 months to 8.9 ± 1.8% at 12 months (p < 0.01). Group 3 (E+caSM): had starting values of HBA1c of 9.5 ± 1.7% and fell significantly (p < 0.01) at 3 months to 8.6 ± 1.6%, then declined slightly to 8.4 ± 1.6% at 12 months (p < 0.01). Group 4, DCCT initiative: significant improvement from baseline (9.2 ± 1.43%) to 7.3 ± 1.4% at 3 months (p < 0.01). Significant improvement from 3 months to 6.7 ± 0.8% at 12 months (p < 0.01). Body weight Group 2 (E+SMT) showed a significant (p < 0.01) change from body weight at baseline (82 ± 15.9 kg) over the next 12 months to (94 ± 18.2 kg). | NR | Cost of care Per member per month charges E-Alone: no additional charges E+SMT: $18 E+caSM: $1.31 DCCT: $11.88 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | Body weight gain occurred in both the DCCT and the education and self-management training initiatives. | NR
An | 2006 | E-mail college students | NA | WWW | Pilot Study and Cohort Study (experimental arm of RCT) | Pilot: 47 Experimental arm of RCT: 257 Studied for technology adherence (RCT): 517 | 2004-2005 | 5 mos | *Students completing survey after an email recruitment *Smoke in the past 30 days *Age 18–24 *In school for next 2 semesters | NR | NR | NR | NR | NR | Pilot: 27.7% RCT: 29.6% | Mean Pilot: 20.1 RCT: 20.1 | NR | NR | All in college | NA | NR | NR | NR | NR | NR | RealU | Pilot: subjects send weekly email asking to track their smoking, take an interactive quiz giving tailored feedback, and Question of the Week (answers posted to discussion board), tobacco topic only; RealU modifications to Pilot: Content on broad topics related to college life rather than only tobacco, users guided weekly to complete Tracker, Quiz, Question of the Week emailed, subjects encouraged to set goals weekly, peer coaches sent emails proactively to those not completing weekly tasks. | Pilot study and RealU experimental arm (not reporting on control group, or outcomes) | Tailored interactive website with email reminders and questions | NR | NR | NR | NR | NA | NA | NA | NR | Website Participation Pilot Study Week 1: 53% Week 2: 21% Week 5: 26% RealU experimental arm Mean: 95% over 20 weeks Range: 89%–98%) | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Andersson | 2005 | Press release, articles, advertisements | NR | Homes | RCT | N = 85 Grp 1:36 Grp 2: 49 Follow up groups Grp 1: 36 Grp 2: 35 | NR | 6 months | *Probability of .55 or more for diagnosis of major depression on CIDI-SFt *Total score on the MADRS-S between 15–30, including a score of less than 4 on item 9 (zest for life) *No psychosis (based on meds status) *No bipolar disorder *No antidepressant meds begun or changed during the last month *No history of cognitive behavioral therapy for depression *Age 18 or older *Prepared to work on self-help program for several hours/week *No travel abroad or major surgery planned *Completion of pre-treatment assessment | NR | NR | NR | DEPRESSION | NR | Grp 1: 22% Grp 2: 28% Withdrawal: 28% | Mean (SD) Grp 1: 36.4 (± 11.5) Grp 2: 36.3 (± 9.9) Grp 3: 35.6 (±10.3) | NR | NR | Education university level Grp 1: 64% Grp 2: 61% Grp 3: 50% | 45% City dwellers | Fewer than 3 self reported episodes of depression Grp 1: 33% Grp 2: 39% Withdrawal: 28% No previous Treatment for depression Grp 1: 44% Grp 2: 39% Grp 3: 44% Current antidepressant medication Grp 1: 22% Grp 2: 37% Grp 3: 28% Baseline BDI (SD) Grp 1: 20.5 (±6.7) Grp 2: 20.9 (±8.5) Grp 3: 21.6 (±7.2) Baseline QoLi score (SD) Grp 1: -0.1 (±1.1) Grp 2: -0.2 (±1.6) Grp 3: -0.2 (±1.1) | NR | NR | Swedish | NR | Internet Based Therapy | Recruiting ads sent those interested to a website. To sign up a computer administered CIDI-SF, MADRS-S and gathered background information. Randomized participants were assigned groups and sent an email with log-in and user name. 89 pages of text as 5 modules were presented. Each module ended with a quiz. Therapist received response and gave email feedback w/i 24h. Participants could read website or download pdfs. 8 weeks was advised for completion. Discussion groups offered separately and monitored. 7 days had to have passed between log ins so depression levels could be monitored. | Group 1: Treatment Group Group 2: Control Group Group 3: Withdrawal Group | Website | Administer psychiatric tests, offer discussion groups, offer therapist feedback. | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | BDI (0–63 range) Pre, Post, pre-post Difference Grp 1: 20.5 (6.7 s.d.), 12.2 (6.8), 8.3 (5.7 to 10.9), Grp 2: 20.9 (8.5), 19.5 (8.1), 1.4 (-1.1 to 3.9) Follow up, Pre to follow up difference Grp 1: n36 - 13.1 (9.1), 7.8 (4.6 to 11.3) Grp 2: n: 35 - 13.1 (7.6), 7.4 (4.0 to 10.7) MADRS-S (range 0–54) Pre, Post, pre-post Difference Grp 1: 20.1 (5.7), 12.7 (8.3), 5.5 (4.6 to 10.1) Grp 2: 21.6 (7.2), 19.0 (7.6), 2.6 (-0.4 to 4.8) Follow up, Pre to follow up difference Grp 1: 14.6 (9.2), 6.3 (3.2 to 9.3) Grp 2: 14.5 (9.3), 6.8 (3.9 to 9.7) | Follow up, Pre to follow up difference | Pre-Treatment, Post treatment, Pre-Post difference Grp 1: -0.1 (1.1), 0.5 (1.6), 0.6 (0.2 to 1.1) Grp 2: -0.2 (1.6), 0.0 (1.5), 0.2 (-0.2 to 0.6) Follow Up and Pre-treatment to follow up difference Grp 1: 0.7(1.7), 0.9 (0.4 to 1.4) Grp 2: 0.9 (1.8), 1.0 (0.5 to 1.4) | Group 1: Treatment Modules and discussion group Group 2: Discussion group only | N = 32 | Those who were not chosen for the treatment group received no help. After the study they were given access to the treatment modules. | Limitations include no formal diagnosis of depression made by clinician, those on med regimens were not excluded, short study
Andersson | 2003 | NR | NA | Homes | RCT | N = 44 (+8 were recruited as controls to receive similar treatment outside the study) Grp 1 (Self help+ telephone): 24 Grp 2 (Self-help only): 20 | NR | 6 weeks | *Pts need to have access to a computer, modem and an internet connection. | Pts with specific cluster headache or sign indicating serious physical or psychological disorders and pts with headache less than 6 months were excluded. Pts with Horton headache, whiplash, head trauma, fibromyalgia, major depression, tinnitus, or other medically unclear neurologic symptoms were excluded. Pts who just submitted the interest form and did not return to the site (or who were not able to call or reach via email) were also excluded. | NR | NR | HEADACHE | NR | N = 8 (18%) Grp 1: N = 4 (17%) Grp 2: N = 4 (20%) | Mean (Range) Grp 1: 36.2 (18–54) Grp 2: 44.9 (25–59) Total: 40.3 (18–59) | NR | NR | NR | NR | Probable diagnosis Migrane Total: 20 Grp 1: 12 Grp 2: 8 Tension type headache total: 15 Grp 1: 9 Grp 2: 6 Tension type headache and migraine total: 5 Grp 1: 2 Grp 2: 3 Nonspecific total: 4 Grp 1: 1 Grp 2: 3 Duration of headache 0.5–1 yr total; 2 Grp 1: 0 Grp 2: 2 1–5 yr total: 14 Grp 1: 10 Grp 2: 4 6–10 yr total: 5 Grp 1: 3 Grp 2: 2 More than 10 yrs total: 23 Grp 1: 11 Grp 2: 12 | NR | NR | NR | NR | Internet based treatment with telephone contact | Therapist initiated telephone contact in the treatment of headache via the internet | The program delivered in 6 weekly treatment modules, information regarding headache and role of psychological factors provided, applied relaxation delivered in separate parts, Rationales, common questions and examples of potential problems added, Relaxation program included various aspects such as tense relax, relax only, cue controlled breathing, rapid relaxation and application training. Weekly report cards for the exercise, problem solving section with pts able to identify, cope with problems including headache related ones. Cognitive behavioral techniques for handling negative thoughts and core beliefs added with part of these being optional. The self help group had all of the above, the self help + telephone group received weekly phone calls for treatment duration scheduled at starting of the treatment, lasting between 5–20 mins and devoted to fostering adherence. Pts in both groups could contact therapists via e mail | Computer | Information, questions and answers, email, learn relaxation techniques with downloadable sound files and online presentation of exercises. | NR | NR | NR | Grp 1 vs. Grp 2 No of subjects- 17 vs. 13 Headache index Pretreatment (pre)- 4.2 (3.7) vs. 3.2 (2.6) Post treatment (post)- 4.0(4.9) vs. 3.1 (2.4) Headache days Pre- 8.4 (4.4) vs. 7.2 (2.8) Post- 8.5 (4.1) vs. 6.4 (3.8) Peak headache Pre- 2.4 (0.6) vs. 2.4(0.8) Post- 2.3 (1.1) vs. 2.7(0.7) Rated intensity Pre- 2.1 (0.7) vs. 2.0(0.8) Post- 2.0(1.1) vs. 2.3 (0.8) Duration Pre- 9.8(6.3) vs. 7.1 (4.1) Post- 7.0(6.7) vs. 9.5(5.4) | NR | NR | NR | NR | NR | Author mentions that most subjects were pleased with the treatment and lack of time was the most common reason for not having practiced to the extent that they wished | NR | Grp 1 vs. grp 2 No of subjects- 15 vs. 9 Questionnaires Hospital and Anxiety depression scale- depression subscale pre- 5.7(4.3) vs. 6.8 (2.5) post- 4.5 (3.9) vs. 4.9(3.3) Hospital and anxiety depression scale- anxiety subscale pre- 8.7(4.8) vs. 7.7 (4.5) posy- 7.9(5.1) vs. 7.0 (4.8) Headache disability inventory pre- 46.6(18.4) vs. 48.4 (13.3) post- 33.6 (16.4) vs. 34.4 (14.8) perceived stress scale pre- 31.3 (7.8) vs. 28.3(3.9) post- 25.7(2.0) vs. 24.7(7.3) | Coping strategies questionnaire Grp 1 vs. Grp 2 No of subjects- 15 vs. 9 Diverting attention Pre- 7.4 (3.6) vs. 7.6 (4.6) Post- 8.6(6.7) vs. 9.6(3.5) Reinterpreting pain sensations Pre- 3.8(5.1) vs. 2.1 (2.6) post- 6.1 (6.1) vs. 4.6 (4.6) Coping self statements Pre- 17.7 (6.4) vs. 16.3 (5.2) Post- 14.7 (5.2) vs. 18.7 (5.5) Ignore pain sensations Pre- 16.9(5.1) vs. 17.1 (3.3) Post- 13.7(3.3) vs. 18.2 (7.0) Praying and hoping Pre- 9.1 (5.2) vs. 13.9(9.2) Post- 8.8 (5.5) vs. 15.4 (10.9) Catastrophizing Pre- 17.1 (7.5) vs. 17.9 (8.8) Post- 11.1 (8.5) vs. 16.0 (8.3) Increased behavioral activities Pre- 11.3 (6.5) vs. 12.0(6.6) Post- 10.4(5.1) vs. 13.2 (7.4) | NR | NR | Dropout rate Grp 1: 29% Grp 2: 35% Difference was not statistically significant N= 44 Grp 1: 24 Completed treatment and registrations: 17 Completed treatment and questionnaires: 15 Failed to respond after exercise modules: 7 Grp 2: 20 Completed treatment and registrations: 13 Completed treatment and questionnaires: 9 Failed to respond after exercise modules: 7 | NR | Significant interaction was found for duration F (1, 28) =7.16, p= 0.012 Post hoc tests showed that the grp 1 had significant decreased duration Number of subjects reaching a 50% decrease in the headache index grp 1 vs. grp2= 29 % vs. 23% the difference was not statistically significant (chi square test) Significant main effect was found on HADS depression subscale F (1,22)=4.53, p=0.045 Disability a/w headache, as measured by HDI decreased significantly for both groups with a main effect of time F(1, 22)= 26.49, p=0.0001 PSS showed main effect of time F (1,22) =7.1, p=0.014 Significant main effect of time was found for subscale reinterpreting pain sensations F (1,22) = 11.2, p=0.029 significant reductions found for catatrophizing with amin effect of time F (1,22) = 7.7, p=0.011 for subscale ignore pain sensation, significant interaction effect was found F (1,22)= 5.3, p=0.031 Significant interaction for the subscale coping self statements F (1,22)= 5.6, p=0.027 Pretreatment characteristics were used to investigate predictors of outcome. details given, not listed here Data about the clinical control sample given (demography as well as results) given, not listed here
Andersson | 2006 | Newspaper articles in national and regional papers, notices in health magazines, and link on homepage of Swedish National Anxiety Association | Sweden | Homes | RCT | N=64 | NR | 1 year | *Fulfill the DSM-4 criteria for social phobia according to the SPSQ *Be afraid of giving a public speech *Have a total score of less than 31 on MADRS-S depression scale and less than 4 on the suicide item of this scale *Undergo no other psychological treatment for the duration of the study and have no history of earlier CBT *If prescribed drugs for anxiety/depression, dosage had to be constant for 3 months before the start of the treatment and the patient had to agree to keep the dosage constant throughout the study *Be at least 18 years or older *Attend an interview that used the SCID *Social phobia had to be the most severe disorder present in the patient *Not a substance abuser | Any criteria against the Inclusion criteria | NR | NR | SOCIAL PHOBIA | NR | IVR: 44% CG: 53% Total: 48.4% | IVR: 36.4 (±9.4) Range: 21–53 CG: 38.2 (±11.0) Range: 18–67 Total: 37.3 (±10.2) Range: 18–67 | NR | NR | Highest educational level (N) Nine-year compulsory school, % IVR: 0, 0 CG: 2, 6.3 Total: 2, 3.1 Secondary school (not completed), % IVR: 1, 3.1 CG: 1, 3.1 Total: 2, 3.1 Vocational school (completed), % IVR: 1, 3.1 CG: 4, 12.5 Total: 5, 7.8 Secondary school (completed), % IVR: 8, 25.0 CG: 7, 21.9 Total: 15, 23.4 College/university (not completed), % IVR: 7, 21.9 CG: 5, 15.6 Total: 12, 18.8 College/university (completed), % IVR: 15, 46.9 CG: 13, 40.6 Total: 28, 43.8 | NR | EMPLOYMENT N, % Full time IVR: 21, 65.6 CG: 21, 65.6 Total: 42, 65.6 Part time IVR: 1, 3.1 CG: 3, 9.4 Total: 4, 6.3 Unemployed IVR: 2, 6.3 CG: 2, 6.3 Total: 4, 6.3 Student IVR: 8, 25 CG: 4, 12.5 Total: 12, 188 Registered sick IVR: 0, 0 CG: 0, 0 Total: 0, 0 Disability pension IVR: 0, 0 CG: 1, 3.1 Total: 1, 1.6 Retired IVR: 0, 0 CG: 1, 3.1 Total: 1, 1.6 TREATMENT HISTORY: N, % Sought help before IVR: 19, 59.4 CG: 17, 53.1 Total: 36, 56.3 Earlier psychological treatment IVR: 5, 5.6 CG: 5, 15.6 Total: 10, 15.6 MEDICATION: N, % When needed IVR: 6, 18.8 CG: 5, 15.6 Total: 11, 17.2 Antidepressive treatment IVR: 0, 0 CG: 3, 9.4 Total: 3, 4.7 | NR | NR | Swedish | NR | NR | Self-help manual that was adapted for use via the internet; divided into 9 modules | IVR: 32 CG: 32 (wait-listed, and received treatment after the IVR group did) | Home computer with access to the internet-access a self-help manual divided into modules | Education, feedback, motivation, encouragement, goal-setting, behavioral experiments, self-focus, safety behaviors | NR | NR | Exposure sessions: two separate 3-hr group exposure sessions facilitated by therapists | Outcome Measures at Each Assessment Point Pretreatment, Post treatment 1 year F/U Effect Size B = btwn grp effect size at post treatment W=w/in grp effect size for treatment grp W/FU=1 yr F/u w/in grp effect size for total grp Liebowitz Social Anxiety Scale IVR: 68.5 (+22.5), 45.6 (+25.1) 39.0 (+21.2) CG: 66.7 (+20.9), 62.8 (+21.7) 46.5 (+21.5) B: 0.73 W: 0.91 W/FU: 1.29 Social Phobia Scale IVR: 35.8 (+16.7), 20.7 (+14.8) 17.8 (+11.6) CG: 32.5 (+13.1), 31.0 (+15.9) 24.2 (+11.8) B: 0.67 W: 0.96 W/FU: 1.12 Social Interaction Anxiety Scale IVR: 44.4 (+16.1), 27.3 (+13.4) 24.8 (+11.1) CG: 44.8 (+12.8), 33.9 (+12.6) 35.0 (+13.2) B: 0.47 W: 1.16 W/FU: 1.09 Social Phobia Screening Questionnaire IVR: 30.4 (+8.7), 20.0 (+8.5) 17.4 (+8.2) CG: 30.2 (+7.6), 28.9 (+7.9) 20.1 (+6.4) B: 1.08 W: 1.21 W/FU: 1.50 Personal Report of Confidence as a Speaker IVR: 25.5 (+4.2), 22.7 (+5.4) 22.1 (+5.9) CG: 25. 9 (+3.5), 25.5 (+4.8) 23.6 (+4.3) B: 0.55 W: 0.58 W/FU: 0.68 Montgomery Asberg Depression Rating Scale IVR: 11.1 (+6.3), 7.0 (+4.7) 7.9 (+5.7) CG: 14.1 (+6.6), 10.7 (+6.2) 9.4 (+6.5) B: 0.68 W: 0.75 W/FU: 0.70 Beck Anxiety Inventory IVR: 13.6 (+7.3), 8.7 (+5.8) 8.2 (+6.6) CG: 13.2 (+6.6), 13.6 (+10.3) 11.2 (+7.7) B: 0.61 W: 0.75 W/FU: 0.61 | NR | NR | NR | NR | NR | NR | NR | NR | Data for the Proportion of Participants Reaching the Criteria of Clinical Significant Improvement as Defined by Jacobson and Truax (1991) %, N Post treatment 1 yr F/u Liebowitz Social Anxiety Scale IVR: 43.3, 13 57.1, 28 CG: 18.7, 6 Social Phobia Scale IVR: 56.3, 18 53.0, 26 CG: 25.0, 8 Social Interaction Anxiety Scale IVR: 60.0, 18 46.9, 23 CG: 37.5, 12 Social Phobia Screening Questionnaire IVR: 73.0, 2 69.4, 34 CG: 15.6, 5 Personal Report of Confidence as a Speaker IVR: 73.0, 22 54.2, 26 CG: 26.7, 8 Montgomery Asberg Depression Rating Scale IVR: 70.0, 21 53.1, 26 CG: 56.2, 18 Beck Anxiety Inventory IVR: 63.3, 19 52.1, 25 CG: 37.5, 12 | QoL Inventory Pretreatment, Post treatment 1 yr F/u B = btwn grp effect size at post treatment W=w/in grp effect size for treatment grp W/FU=1 yr F/u w/in grp effect size for total grp IVR: 1.5 (±1.1), 2.2 (±1.2) 2.2 (±2.1) CG: 1.1 (±1.4), 1.1 (±1.7) 1.6 (±2.4) B: 0.83 W: 0.61 W/FU: 0.43 Data for the Proportion of Participants Reaching the Criteria of Clinical Significant Improvement as Defined by Jacobson and Truax (1991) %, N Post treatment 1 yr F/u QoL Inventory IVR: 66.7, 20 53.1, 26 CG: 34.4, 11 | NR | 2 people dropped out during the course of the study 12 failed to finish all weekly modules 2 pts did not return their questionnaires | NR | NR
Andrade | 2005 | NR | The John Hopkins Moore HIV clinic in Baltimore | disease management assistance system device | RCT | N= 64 Intervention grp (IG): 32 Control group (CG): 32 | 1999 to 2001 | 24 weeks | *Age ≥18 yrs *Able to self medicate *Currently receiving care at John Hopkins Moore clinic *Subjects were either previously treatment naïve and initiating HAART for the first time or antiretroviral experienced and switching HAART regimen *In the latter group, only those who received ≤ 3 HAART regimens before study enrollment included | Inability to self medicate; presence of severe dementia; and institutionalization. | NR | NR | HIV | NR | IG: 16 (55) CG: 18 (62) | IG: 38 (±7) CG: 38 (±7) | Black IG: 26 (90) CG: 25 (86) | NR | NR | NR | CD4 cell counts, IG vs. CG: 235 (±141) vs. 213 (±245) Plasma HIV RNA load, IG vs. CG: 4.4 (±0.2) vs. 4.3 (±0.2) Memory impaired IG vs. CG: 14 (48%) vs. 17 (59%) Neuropsychological test scores, details on AIDS, Drug use in the past 4 days, Methadone treatment, HAART status at study entry, CES-D analysis given, not listed here. (No differences between the two groups were statistically significant) | NR | NR | NR | NR | The disease management assistance system (DMAS) | The DMAS is a portable battery powered electronic device that uses a digital signal processor to produce a timed, programmed voice message that prompts subjects to take their antiretrovirals. When a subject pushes a response button, the data can be uploaded and printed. The device can store up to 3 months of messages for up to 25 different medications. | All subjects attended an individualized, 30 min adherence counseling session each month and received adherence feedback from a standardized transcript that provided general education about barriers to adherence, hazards of non adherence and their prescribed HAART regimen. Mean adherence scores obtained from eDEM caps. IG group- provided with DMAS programmed with HAART regimen data to provide verbal reminders at dosing time. When a subject pushes a response button, the data can be uploaded and printed. CG- received only adherence counseling. | Battery powered electronic device | Voice reminders, storage of dosage times and dates. | NR | Subjects trained on usage of eDEM caps | NR | Plasma HIV RNA loads Week 12 IG vs. CG: Undetectable plasma loads: 38% vs. 14%, p=0.014 Week 24 IG vs. CG: Undetectable loads: 34% vs. 38%, p=0.49 Week 12 IG vs. CG: Decrease in load of at least 1 log_10_ copies/mm3: 55% vs. 41%, p= 0.098 Week 24 IG vs. CG: Decrease in load of at least 1 log_10_ copies/mm3: 72% vs. 41%, p=0.02 Overall mean reductions IG vs. CG: -2.10 vs. -0.98, p=0.02 Mean CD4 cell counts Week 12 IG vs. CG: 337 (±183) vs. 258 (±184), p=0.14 Week 24 IG vs. CG: 301 (±172) vs. 250 (±172), p= 0.28 Overall increase IG vs. CG: 68 vs. 45, p=0.62 | NR | NR | NR | Week 20: 88% of pts in IG reported that they used the device some or all of the time to manage HAART use. 1 subject reported never having used the device. | NR | NR | NR | NR | Mean percentage adherence (SE) IG vs. CG Week 4: 76 (5.7) vs. 69 (5.2) Week 8: 75 (6.3) vs. 68 (6.1) Week 12: 87 (4.9) vs. 64 (6.3) Week 16: 83 (5.9) vs. 62 (7.4) Week 20: 80 (5.8) vs. 61(7.3) Week 24: 80 (6.3) vs. 64 (8.2) Overall: 80 (2.3) vs. 65(2.7) Mean adherence percentage (SE) impaired memory (IG : CG) vs. intact memory (IG : CG) Week 4: 70 (8.8) : 63(6.8) vs. 82 (7.0) : 77 (7.7) Week 8: 75(8.8) : 62 (8.4) vs. 70 (9.4) : 76(8.5) Week 12: 81 (7.3) : 56 (8.4) vs. 88 (7.7) : 77 (8.1) Week 16: 72 (9.3) : 55 (9.8) vs. 91 (6.2) : 76(9.6) Week 20: 73 (7.5) : 49(8.7) vs. 86 (8.9) : 80 (9.3) Week 24: 79(10.8) : 56 (10.6) vs. 82 (8.0) : 76 (12.5) Overall: 77 (3.4) : 57(3.5) vs. 83(3.3) : 77 (3.5) Among memory impaired subjects, scores were statistically significant and greater in the IG (p=0.001) | NR | NR | Intervention group: 1 died, 1 lost to follow up, 29 included in ITT analysis Control group: 3 lost to follow up, 29 included in ITT analysis | NR | Virological and immune responses to medication between memory impaired and memory intact given, not listed here (NS).
Andrade | 2001 | Johns Hopkins | NR | Home/with patient | RCT | N=50 | 6 months | NR | *Patients who were starting highly active antiretroviral therapy for the first time or who had failed it once or twice in the past | NR | NR | NR | HIV/AIDS | NR | NR | NR | American | NR | NR | NR | NR | NR | NR | English | NR | Disease Management Assistance System (DMAS) | The DMAS emits a beeping sound when patients are supposed to take their medication. They then press “play” button on the DMAS and the device plays a verbal medication reminder. Once the patients have taken their medication they press the “yes” button and the device records the date and time of their medication. | IVR Grp: 50 CG: 50 | Pager like | Medication reminder, adherence recorder | NR | NR | Monthly antiretroviral education and counseling | Viral loads (Mean) IVR: 1.5 log decrease CG: 0.5 log decrease CD4 cell count (Mean) IVR: 50 CD4 cell increase CG: 10 CD4 cell increase | NR | NR | NR | Preliminary data analysis of the first 19 patients (of 86, 52 who were enrolled through June 2001) showed a mean adherence score of 92% for IVR and 83 for CG. Memory-impaired subjects in IVR group had adherence of 90% vs. 80% in CG. | Reported that younger employees tended to use the e-mail as a communication tool for health counseling more than older employees, and there are different levels of skill and acceptability for e-mail among employees in administrative and manufacturing divisions | NR | NR | NR | NR | NR | NR | NR | NR | All pts were also given EDEM caps which recorded the time and date pts took medications, to help verify the accuracy of the DMAS recording system
Andrewes | 1996 | NR | General teaching hospital (Royl Melbourne hospital) and a private hospital (Melbourne clinic) | Homes | Pre- post | N= 54 Grp 1 (DIET): 27 Grp 2 (CARL): 27 | NR | NA | NR | NR | NR | NR | Yes- DSM-III-R diagnosed eating disorders (anorexia nervosa and bulimia) | NR | NR | Age in years - Mean (SD) DIET vs. Control: 22.4 (±5.6) vs. 21.6 (±5.0) | NR | NR | NR | NR | NR | NR | NR | NR | NR | DIET | Health education package containing information aimed at educating patients on issues regarding the dangers and myths surrounding certain methods of dieting and the underlying mechanism which have been found to maintain eating disorders | Grp 1 (DIET): Aim of the program is to educate about anorexia and bulimia and to debunk some of the myths concerning weight control. Areas covered were laxative inefficiency, adverse effects of self induced vomiting, rebound effect of diuretics, effects on the brain due to starvation, natural metabolic rate drops, myths surrounding weight loss and exercise, weight reduction and self esteem, media influence, challenging aspects of puberty and family influences. Grp 2 (CARL): Subjects interacted with the CARL program by typing in responses to questions. on directional counseling stimulation. | Computers | Health education, questions and answers (typing in responses) | NR | NR | NR | NR | NR | NR | Eating disorder knowledge questionnaire Grp 1 vs. Grp 2 mean (SD) Pre intervention: 30.1 (±8.0) vs. 34.4 (±8.0) Post intervention: 44.4 (±10.8) vs. 37.1 (±7.9) F (1, 50)= 50.3, p ≤ 0.001 | NR | Ease of use, Mean (SD) Grp 1: 8.5 (±2.6) to 9.8 (±0.6) Difficult to operate : Grp 2: 4.6 (±2.6) | Mean (SD) Usefulness and relevance Grp1: 7.1 (±2.9) to 8.6 (±2.0) Wanting to receive more info 6.3 (+2.5) to 7.9 (±2.2) Grp 2: Not useful: 2.0 (±1.5) Not enjoyable: 4.1 (±3.0) | Eating disorder attitude questionnaire, Mean (SD) Grp 1 vs. Grp 2 Pre-intervention: 149 (±42.7) vs. 148.6 (±40.4) Post-intervention: 166.9 (±49.0) vs. 149.5 (±41.9) F (1,50) = 6.8, p=0.01 | NR | NR | NR | NR | NR | NR | NR
Anhoj | 2004 | WWW | NR | WWW | Cohort (survey, interview) | User online survey: 85 Provider mail survey: 131 Interview: 15 | 2002 | NA | *Survey responders | NR | NR | NR | ASTHMA | NR | 29% (N = 17/59) | Mean Male: 41 Female: 36 | NR | NR | NR | NR | NR | NR | NR | NR | NR | LinkMedica | Website with tailored feedback and support | NA | WWW | Web-based diary, graphic report of peak flow, medication management feedback, knowledge center, support group, ask the expert | NR | NR | NR | NA | NR | NR | NR | NR | NR | Users rated quality of website functions, but combined patients and providers and survey instrument very poor | NR | NR | NR | NR | NR | NR | NR | Qualitative description of users, categorized as ‘controllers’ or ‘disease neglecters’; patient users felt “doctors ignorant”
Araki | 2006 | Manufacturing Plant | NR | Manufacturing plant | RCT | N=36 | 2 months | NR | *Employed at a manufacturing plant in Tokyo *Had health data (for the annual checkup) available as of May 20th *Abnormal levels of gamma-GTP | Requiring immediate medical attention, past history of hepatic dysfunction, those who drank less than once a month | NR | NR | ALCOHOLISM | NR | 100% | Mean Age (SD) Grp 1: 43.4 (±8.1) Grp 2: 44.3 (±7.2) Grp 3: 43.8 (±7.3) | Japanese | NR | NR | NR | NR | NR | NR | Japanese | Based on the Knowledge-Attitude-Behavior (KAB) model, precise knowledge on appropriate drinking behaviors would likely lead to a favorable attitude to adopting an appropriate behavior, and in turn it would result in an actual behavior | NR | E-mail counseling or face-to-face counseling that included short lectures on potential health risks of excess alcohol consumption and appropriate drinking behaviors. Also included goal setting. | Grp 1 (Face-to-Face): 12 Grp 2 (Email): 12 Grp 3 (CG): 12 | Computer/email, brochure, live counselor | Email was used to encourage cessation of heavy drinking and often used attached brochures Face-to-face counseling employed real counselors and used brochures as well | NR | NR | NR | [underlined: Baseline] Reported alcohol consumption (g Ethanol/day) Grp 1: 24.8 (±15.7) Grp 2: 35.0 (±18.6) Grp 3: 19.8 (±17.9) p=0.1074 Serum gamma-GTP Grp 1: 140.7 (±63.6) Grp 2: 138.1 (±65.4) Grp 3: 117.4 (±40.2) p=0.5613 [underlined: After IVR] Grp 1: 116.3 p=0.05 Grp 2&3: not significant change | NR | NR | NR | NR | Reported that younger employees tended to use the e-mail as a communication tool for health counseling more than older employees, and there are different levels of skill and acceptability for e-mail among employees in administrative and manufacturing divisions | NR | NR | NR | Baseline/After IVR Knowledge: Grp 1: 3.2 (±1.7)/5.9 p<0.001 Grp 2: 4.2 (±1.1)/4.8 Grp 3: 3.6 (±2.2)/NS Baseline p=0.3654 Attitude: Grp 1: 5.6 (±2.2)/7.1 p<0.05 Grp 2: 5.2 (±2.5)/NS Grp 3: 6.6 (±2.1)/NS Baseline p=0.3521 Behavior: *see physiologic | NR | NR | NR | NR | NR
Armstrong | 2005 | Patients at Cancer Risk Evaluation Program at U of Pennsylvania were screened for inclusion | NR | NR | Double blind RCT | N = 27 Grp 1: 13 Grp 2: 14 | 2000-2003 | 6 weeks | *Have undergone oophorectomy or mastectomy | No significant residual breast or ovarian cancer risk, those with ovarian cancer or metastatic breast cancer | NR | NR | CANCER Risk, BRCA 1/2 Mutations | NR | N = 0% | Mean (Range) Total: 43 (26–59) Grp 1: 45 (30–59) Grp 2: 42 (26–54) | Caucasian: 100% | NR | Overall 74% College educated Grp 1: 70% Grp 2: 85% | NR | NR | NR | NR | English | NR | Tailored Decision Support System | Provides individualized survival and cancer incidence curves specific to outcomes of alternative management strategies | Group 1: Intervention Group 2: Control | Computer was used to create curves, unclear as to patient interaction | Offer decision strategies for dealing with BRCA 1/2 | NR | 1:1 meeting with research coordinator, review of educational booklet | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | 5-3 unable to travel or commit to see research coordinator, one underwent prophylactic mastectomy and oophorecotmy, 1 unreachable for follow up | NR | NR
Artinian | 2003 | Urban, Detroit VA medical center | Urban CHF clinic | Homes | RCT | N=18 Grp 1 (Usual care) :9 Grp 2 (Usual care+ compliance device) : 9 | NR | 3 months | *Age equal to or more than 18 yrs *Symptomatic left ventricular dysfunction *Ejection fraction of 40% or less *Ownership or rental home with a telephone *Ability to read and understand English *Plans to remain in the city for the study period | H/o dementia, mental illness, symptomatic infectious disease or advanced liver disease, self reported substance abuse, hemodialysis, coronary angioplasty within last 60 days or coronary artery bypass graft surgery within last 90 days, inability to participate in 6 min walk test or terminal stages of cancer | NR | NR | CHF | NR | N = 17 (94%) | Mean (SD): 68 (±11 yrs) | Black: 65% (11 pts) Caucasian: 35% (6 pts) | < $ 10,000: 2 pts (13%) $10,000–19,000: 8 pts (53%) $ 20,000–29,999: 4 pts (27%) >$ 40,000: 1 pt (6%) *3 pts chose not to disclose their income | Mean educational level: 13 yrs Range: 8–19yrs | Urban | Marital status Unmarried: 14 pts (78%) Single: 2 pts (11%) Divorced/separated: 10 pts (56%) Widowed: 2 pts (11%) Married: 4 pts (22%) Live alone: 11 pts (61%) Live with spouse or child: 7 pts (39%) | NR | NR | NR | NR | Med-eMonitor | *Med-eMonitor device-5 compartments for supplying up to 5 medications using alarm to remind the pts daily when to take, which to take and how many to take. *25 virtual compartments with daily tailored reminders or questions regarding other medications, monitoring, daily weight and BP, reducing salt intake, eating heart healthy and engaging in physical activity *Date and time stamped record of pill taking *Recordings of pts's responses to specific questions *Updates to pts's regimen downloaded and pts info automatically transmitted to server via telephone | Grp 1 : usual care + web based intervention (compliance device) Grp 2: Usual care All received self care behavior booklet, Grp 1 included visits to the cardiologist in the clinic at regular intervals (frequency determined by severity of HF). On each visit, pharmacist assesses medication taking and provided pts with written info about name, frequency and action of medication. Grp2 received all above + Med- eMonitor | Videocassette (Med - Monitor) that sat in a cradle connected to a telephone line | Compliance device with alarms and reminders, daily monitoring of weight and BP, and answers to specific questions | NR | All pts received an educational booklet describing CHF self care behaviors pts were instructed on how to use their weight scale and BP monitor | Unclear | Functional status Grp 1 vs. Grp 2 NYHA Functional class Baseline Mean (SD) 3 (±0.83) vs. 3 (±0.50) 3 month Mean (SD) 3 (±1.01) vs. 2 (±1.01) ANOVA Time---F(1,16)=0.67,p=0.424 Group by time interaction-F(1,16)=0.00,p=1.0 6 MWT distance in feet Baseline Mean (SD) 846 (±347) vs. 946 (±294) 3 month Mean (SD) 983(±299) vs. 995 (±257) ANOVA Time— F(1,16)=1.28,p=0.276 group by time interaction-F(1,16)=0.00,p=0.968 | NR | NR | NR | NR | Technical difficulties Difficulties with monitor: 4 pts (44%) Difficulty getting out small pills from compartments: 4 pts(44%) Difficulty reading the screen: 2 pts Color of lettering hard to see: some pts Message needs to be long enough for clarity: many Could not hear beep of the monitor: 1 pt | Loved it: 5pts(56%) Hated it: 4 pts (44%) Quotes of the pts included, not listed here | Changing lifestyles (i.e. helped establish better routines): 6 (67%) | NR | Self care behaviors Grp 1 vs. Grp 2 Baseline Mean(SD) 95 (±22) vs. 92 (±8) 3 month Mean (SD) 108 (±22) vs. 106 (±21) ANOVA Time: F(1,16)=6.81,p=0.019 Grp by time interaction: F(1,16)=0.02, p=0.902 Post hoc paired samples t test Grp 1: t (8)= 1.85, p=0.102 Grp 2: t (8)=1.85, p= 0.102 Compliance with daily monitoring Weight: Grp 1 vs. Grp 2: 79% vs. 85%, t (15)= 0.57,p=0.577 BP: Grp 1 vs. Grp 2 : 51% vs. 81%, t (15)= 1.83, p= 0.095 Grp 2 rates as measured by monitor Average compliance rates for with weight and BP: 96% Medication compliance rate: 94% | Total Quality of life (QOL) Grp 1 vs. Grp 2 Baseline mean (SD) 43 (±22) vs. 51 (±24) 3 month mean 28 (±27) vs. 38 (±25) ANOVA Time: F (1,16) = 10.00, p= 0.006 Grp by time interaction-: F (1,16)= 0.05, p=0.832 Post hoc paired samples t test Difference between baseline and follow up mean Grp 1: t (8)=1.78, p=0.113 Grp 2: t (8)=4.63, p=0.002 Physical QOL Grp 1 vs. Grp 2 Baseline mean(SD) 21 (±13) vs. 26 (±9) 3 month mean 14 (±11) vs. 19 (±11) ANOVA Time: F (1,16)= 6.20, p=0.024 Grp by time interaction: F (1,16)= 0.03, p=0.868 Magnitude of improvement Grp 1: t (8)=1.21, p= 0.262 Grp 2 : t (8)= 4.88, p= 0.001 Emotional QOL Grp 1 vs. Grp 2 Baseline mean (SD) 5 (±9) vs. 8 (±6) 3 month mean 5 (±8) vs. 7 (±7) ANOVA Time: F (1,16)=1.00, p=0.333 Time by group interaction: F (1,16)=0.07,p= 0.789 | NR | NR | NR | Clinical characteristics of sample at baseline viz NYHA FC, Perceived health, smoking, BMI -given but not listed here Cronbach alpha values for reliability across time given, not listed here
Bachofen | 1999 | NR | NR | Homes | Cohort | N=21 | NR | 3 mos | NR | NR | NR | NR | OCD | NR | N = 56.6% | Mean (SD): 31 (±8.2) Range: 21–54 | NR | NR | NR | NR | Mean age at onset of OCD (SD): 19 (±6.1) Range: 10–34 Mean OCD duration (SD): 12 yrs (±6.9) Range: 2–28 yrs OCD rituals (N) Washing: 4 Checking: 9 Harming self or others: 6 Numbers: 4 Perfectionism: 3 All but 1 taking psychotropic medication at the time of study | NR | NR | NR | NR | Self therapy with BT steps | Self-guiding manual and touch tone phone used to access computer driven interviews via an interactive voice response system | Pts given 190 pg BT STEPS manual and a PIN to access the IVR system A toll free call could be made from any touch tone telephone in the UK to a computer in Madison, WI Coordinator explained steps, pts left to personalize their self treatment program under guidance of the manual and the IVR system After call completion, computer generated and faxed a feedback sheet that summarized the call. After pts started doing the ERP sessions, a personalized ERP homework diary sheet, based on the goals they had entered, was mailed to them each week Pts who did not call the IVR system for a week were contacted by phone or mail to inquire the reason. | Touch Tone telephone | Question and answers, feedback sheet, personalized ERP diary sheet, helped personalize self treatment program | NR | A coordinator spent 5 mins with each pt, explaining how to use the BT steps and make IVR calls and encouraging daily use of the system. For pts who lived far away, manual was mailed and coordinator explained the steps over the phone | NR | Y-BOCS (Yale Brown Obsessive Compulsive scale) Total Baseline vs. Completers (12 week), Mean (SD) 25 (±6.2) vs. 20 (+7.5) Completers (N=19) (t, df, p) vs. ITT analysis (t, df, p) 3.19, 18, 0.005 vs. 3.12, 20, 0.005 Rituals Baseline vs. Completers (12 week), Mean (SD) 13 (±3) vs. 10 (±4.4) Completers (N=19) (t, df, p) vs. ITT analysis (t, df, p) 3.54, 18, 0.002 vs. 3.43, 20, 0.003 Obsessions Baseline vs. Completers (12 week), Mean (SD) 11 (±3.8) vs. 10 (±3.4) Completers (N=19) (t, df, p) vs. ITT analysis (t, df, p) 1.89, 18, 0.074 vs. 1.88, 20, 0.075 PGI- Patient Global impression scale Completers (12 week), Mean (SD) 2.8 (±1.0) | NR | The cost of the system compares favorably to that of medication and clinician guided care. They save 80 % of the per patient time needed by a clinician to guide ERP | NR | Pts used the IVR system over a period of 67.2 (±38.3) days Pts took a mean of 34.6 (±26.5) days from the time they made call 1 until they completed their first ERP session Pts who did 2 or more ERP sessions took a mean of 64 days doing ERP after completing call 4 | NR | NR | NR | NR | Hamilton rating scale for depression Baseline vs. Completers (12 week), Mean (SD) 22 (±8.1) vs. 17 (±8.3) Completers (N=19) (t, df, p) vs. ITT analysis (t, df, p) 2.99, 18, 0.008 vs. 2.93, 20, 0.008 Work and social adjustment scale Total Baseline vs. Completers (12 week), Mean (SD) 20 (±7.3) vs. 17 (±7.6) Completers (N=19) (t, df, p) vs. ITT analysis (t, df, p) 2.28, 18, 0.035 vs. 2.27, 19, 0.035 Work item Baseline vs. Completers (12 week), Mean (SD) 5.2 (±2.7) vs. 4.5 (±2.3) Completers (N=19) (t, df, p) vs. ITT analysis (t, df, p) 1.49, 18, 0.154 vs. 1.49, 19, 0.153 Home management Baseline vs. Completers (12 week), Mean (SD) 6.1 (±1.6) vs. 4.9 (±2.2) Completers (N=19) (t, df, p) vs. ITT analysis (t, df, p) 2.15, 17, 0.046 vs. 2.14, 18, 0.047 Social leisure Baseline vs. Completers (12 week), Mean (SD) 4.9 (±2.6) vs. 4.2 (±2.5) Completers (N=19) (t, df, p) vs. ITT analysis (t, df, p) 1.37, 17, 0.187 vs. 1.37, 18, 0.187 Private leisure baseline vs. Completers (12 week), Mean (SD) 4.6 (±2.2) vs. 3.1 (±2.6) Completers (N=19) (t, df, p) vs. ITT analysis (t, df, p) 2.63, 17, 0.018 vs. 2.60, 18, 0.018 | NR | NR | 2 pts had to leave the study as their turn on the waiting list arrived to begin clinician guided therapy | NR | Data on improvement in OCD patients who completed 2 or more versus 1 or no exposure and ritual prevention session given, not listed here
Barnason | 2003 | 4 Midwestern hospitals | Hospital | Homes | RCT w/ repeated measures | N = 35 HCI (experiment): 18 RC (control): 17 | NR | 3 months | *From previous parent study of N = 180 *Ischemic Heart Failure (HF) *CABG *Written consent *Age ≥65 | Age < 65 yrs | Yes: Range 65 –85 yrs. | NR | CAD | NR | HCI: 78% RC: 59% | Mean (SD) HCI: 73.72 (±5.06) RC: 72.82 (± 4.80) | NR | NR | NR | NR | “There were no statistically significant differences by group for any of the demographic characteristics (age, gender, or length of hospital stay)’ | NR | NR | NR | NR | Health Buddy | Small device attached to patient's telephone. Provides assessment, strategies, education, and positive reinforcement | Group 1: (Home Communication Intervention): Health Buddy: daily session Group 2: (Routine Care): RC consisted of the usual patient education and counseling provided to all CABG subjects prior to hospital discharge. Ability to ask questions: NR. | Phone attachment /screen | Provides daily: assessment, strategies, education, and positive reinforcement | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | Self-efficacy score: [F (1,29) = 6.40, P < 0.02] HCI: 50.6 (standard error = 1.1) RC: 46.5 (standard error = 1.1) | Salt Fewer subjects HCI subjects reported the use of salt when cooking and eating at 4 weeks, 6 weeks, and 3 months postoperatively. There was as significant difference at 4 weeks using salt with cooking (X2 = 6.92, P > .01): RC: 47.1% HCI: 6.3 % Exercise Adherence The HCI group reported significantly higher exercise adherence (t = 3.09, P < .01) and stress control (t=3.77, P < .01) at 3 months postoperatively. | Physical Functioning HCI subject has significantly [F(1,29) = 4.56, P <.04] higher adjusted physical functioning mean scores (Mean: 84.4, SD: ±3.9) compared with the RC group (Mean:71.5, SD: ±3.9) General Health Functioning HCI subjects had significantly [F(1,29) = 6.99, P <.01] higher adjusted general health functioning mean scores (Mean: 79.8, SD: ±2.9) compared with the RC group (Mean: 69.4, SD: ±2.8) Pain There was a significant time effect [F(1,29)=11.25, P <.002] on the pain subscale both HCI and RC: 6 weeks: 77.4 (±3.3) 3 months: 87.8 (±3.7) Mental Health HCI subjects had significantly [F (1,29)= 8.33, P <.007] higher mental health functioning (Mean: 88.7, SD: ±3.09) compared with RC group (Mean: 78.0, SD: ±3.0). Validity HCI subjects had significantly [F (1,29)= 7.16, P <.01] higher validity functioning (Mean: 69.5, SD: ±4.1) compared with RC group (Mean: 57.1, SD: ±4.0). Role Emotional Functioning There was a significant time effect [F(1,29)=11.25, P <.002] on the role emotional functioning both HCI and RC: 6 weeks: Mean: 94.1 (±4.2) 3 months: Mean: 80.9 (±6.9) | NR | NR | NR | NR
Barnason | 2006 | Convenience sample | “Midwestern Medical Center” | Homes | Randomized, experimental two-group repeated measures design | N = 50 | NR | 3 months | *Speak/read English *Have telephone service *Undergoing coronary artery bypass graft *Pre-discharge *Ages 65 and older | NR | NR | NR | CORONARY ARTERY DISEASE | NR | 56% | Mean: 75.3 | NR | NR | NR | NR | NR | NR | NR | English | NR | Health Buddy | 12 weeks of a desktop telehealth device with daily interventions with recovery assessment, strategies to manage problems, education and positive reinforcement | Group 1: Experimental - received Healthcare Intervention (HCI) Group 2: Control - Routine care (HHC) | Desktop telehealth device | Illuminated screen with 4 large buttons - daily feedback | NR | Screened for vision and key use no reported training | Medical Outcomes Short Form-36 at 6 weeks and 3 mos. after bypass. Physiological Functioning Scales: IVR mean 77.6, CG mean 69.59 Time improvement Physical: (F [1,36]=9.42, P<.01) Role Physical: (F[1,36]=5.74, P<.05) Time Effect Mental Health: (F[1,36]=7.97, P<.01) both groups | Non-Routine provider visits: IVR mean 2.8,CG mean 2.61 Emergency room visits: IVR 1 subject, CG 6 subjects, but not stat. significant (squared =2.1, P=.15) Nursing visits: IVR avg. 9.68(±5.4), CG avg. 7.48(±6.8) | NR | NR | NR | NR | NR | NR | NR | Self report instrument developed by research team | NR | WITHIN group time effects differences: Both groups improved: Mental Health: (F[1,36=7.97, P<.01) other within group mental health outcomes listed. | NR | NR | Chest pain, fluid in leg, pneumonia, heart failure, wound infection, dysrhythemias, blood clot: leg, Very nervous, GI problems, constipation | NR
Barrera | 2002 | 16 Primary care medical practices | Primary care medical practices | Homes | RCT | N= 160 CG: 40 Coach: 40 Social Support: 40 Social Support + Coach: 40 | NR | 3 mos | *Age: 40–75 years old *Live in local area *Have a telephone *Read and write English *Be diagnosed with Type 2 diabetes for least 1 year *Did not previously have Internet access at home or work | NR | NR | NR | TYPE 2 DIABETES | NR | N = 46.9% Control: 47.5% Coach: 42.5% Social Support: 52.5% Social Support + Coach: 45% | Mean (SD) Total: 59.3 (±9.4) Control: 60.8 (±9.1) Coach: 57.6 (±9.1) Social Support: 56.7 (± 9.2) Social Support plus Coach: 62.1 (± 9.5) | NR | [underlined: Income] (this was a 6-point scale where 1 = less than $10,000, and where 6 ≥ $50,000) N = 160, 2.9 (1.4) Control: (n=40), 2.9 (1.2) Coach: (n=40), 2.7 (1.4) Social Support: 3.1 (1.6) Social Support + Coach: 2.7 (1.3) | Education (This was a 7-point scale where 1 = 6th grade or less, 2 = 7th – 9th grade, 3 = 10th – 11th grade, 4 = high school graduate, 5 = some college, 6 = college graduate, 7 = graduate or professional school) N = 160, 4.8 (1.3) Control: (n=40), 4.8 (1.2) Coach: (n=40), 5.0 (1.2) Social Support: 4.7 (1.4) Social Support + Coach: 4.9 (1.3) | NR | NR | NR | English literate | English | NR | NR | This study used a new measure that was designed to provide a fair evaluation of a Internet-based support group that focused on diabetes. Information Only computer access to an extensive number of informational articles that concerned medical, nutritional, and lifestyle aspects of diabetes. Personal Coach Only Information Only intervention plus they had computer-mediated access to a professional who had expertise in providing dietary advice to diabetes patients. Participants worked with their coach, viewed resources via the web, had access to an online dietary conference, and accessed a personal database where they could enter information on their daily intake of fruits, vegetables, and saturated fat. They also could enter their blood glucose levels for different periods of each Day. Social Support Only Information Only intervention plus several activities that provided participants with opportunities to exchange diabetes-related information, coping strategies, and emotional support over online discussion boards. In addition to these support activities, participants could also engage in real-time live-chat discussions. Combined Condition Participants in the combined condition had access to the same resources that were available in the Personal Coach condition and the Social Support condition. | Computers with internet access. Social support websites with forums, live chat, and informational articles. | Computer-based interventions to assess changes in participant perceptions of social support. | NR | NR | Each participant received training in using the features of the computer that would allow them to access and navigate the website. | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | Age was significantly related to change on the DSS, r(123) = -.22, p < .05, and did not show interactions with this condition. Age (as covariate) and DSS change scores (as criterion), ANCOVA showed significant effect for both age, F(1,118) = 6.46, p < .05, and condition, F(3, 118) = 4.88, p < .01, f = .33. Information controls contrasted with Social Support Only and Combined Conditions that contained Internet-based social support was significant t(119) = -3.82, p < .001. | Total = 37. Support group = 10, Information, personal coach, and combined condition groups: 9 each. No significant effects for condition or interaction between groups. | NR | NR
Block | 2004 | NR | Berkeley, California | Homes | RCT | N=491 | 9 months | NR | *Female *African American or non-Hispanic white *Age 40–65 yrs *Low-income | Any criteria against the Inclusion criteria | NR | YES Below poverty: 68.0% 100–185% of poverty: 24.5% Above 185% of poverty: 7.5% | NR | NR | 0.00% | 50.1 (39–65) | African American: 48.4% White non-Hispanic: 51.6% | <$10,000: 23.3% 10,000–15,000: 9.6% 15,000–20,000: 8.5% 20,000–25,000: 7.7% 25,000–35,000: 17.1% 35,000–50,000: 11.6% 50,000–65,000: 6.7% >65,000: 15.6% | Elementary only: 0.6% Junior high only: 2.1% HS grad: 31.0% More than HS: 66.3% | NR | Fruit and vegetable occurrence/day 0: 6.2% 1: 15.4% 2: 18.3% 3: 15.6% 4: 16.6% 5 or more: 27.9% | NR | NR | NR | Research overwhelmingly implicates low intakes of fruits and vegetables as factors influencing the prevalence of several chronic disease and poor health | Little by Little | CD-ROM that includes a brief assessment of fruit and vegetable intake as well as messages and tips to increase intake | CD-ROM Only: 160 CD-ROM + 2 phone calls: 162 CG: 159 | CD-ROM | To increase the level of fruit and vegetable intake by low-income women | Interviewers were provided with scripts for the two brief telephone calls made to the CD-ROM + telephone call groups | NR | NR | Change in Fruit/Vegetable Occurrences: CD-ROM + telephone calls: 1.32, p=0.016 CD-ROM only: 1.20, p=0.052 CG: 0.71, p=NA | NR | NR | NR | NR | NR | NR | NR | NR | Change in Stage of Readiness for Change CD-ROM Only: 0.41, p=0.01 CD-ROM + phone calls: 0.31, p=0.15 CG: 0.17, p=NA | NR | NR | N=10 | NR | NR
Brennan | 2001 | Hospital | NR | Homes | RCT | N = 140 Grp 1: 50 Grp 2: 50 Grp 3: 40 | NR | 6 mos | NR | NR | NR | NR | CABG | NR | N = 78% | Mean (Range): 63.4 (38–82) | Caucasian: 86% African American: 12% | NR | NR | NR | NR | NR | NR | NR | NR | HeartCare | Computerized, internet-based information and support system that provides extension and enhancement of traditional nursing services | Group 1: HeartCare Group 2: CHIP Group 3: Usual care | Computer/internet | Education, support, tailored health information | None | NR | NR | NR | NR | NR | NR | For one week snapshot: Group 1 used the HeartCare system a total of 451 times, an average of 64 accesses per day | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Carlbring | 2007 | NR | NR | Homes | RCT | N= 57 IVR: 29 CG: 28 | NR | 1 year | *Fulfill the DSM-4 criteria for social phobia according to the SPSQ *Have a total score of below 31 on MADRS-S depression scale and a score of less than 4 on the suicide item of this scale *Agree to undergo no other psychological treatment for the duration of the study, and have no history of earlier cognitive- behavior therapy *If taking prescribed drugs for anxiety or depression, the dosage had to be constant for 3 months before the start of the treatment, and the participants had to agree to keep the dosage constant throughout the study *Have access to a computer with internet connection *Be at least 18 yrs old *Live in Sweden *Be able to speak to the therapists by phone on a weekly basis *Following telephone administration must have social phobia as the primary diagnosis if other co morbid conditions present *Not currently meet diagnostic criteria for psychosis or substance abuse | NR | No | NR | SOCIAL PHOBIA | NR | IVR vs. CG: 41 % vs. 29% | Mean (SD) IVR vs. CG: 32.4 (±9.1) vs. 32.9 (±9.2) | NR | NR | Education % IVR vs. CG Elementary: 7 vs. 7 High school Not completed: 0 vs. 4 Completed: 28 vs. 18 Community college: 3 vs. 4 College/university Not completed: 34 vs. 34 Completed: 28 vs. 32 | NR | Self-rated computer experience IVR vs. CG Far above average: 34 vs. 32 Above average: 24 vs. 21 Average: 34 vs. 32 Below average: 7 vs. 14 | NR | NR | NR | NR | Cognitive behavioral therapy with telephone support | 9 week Internet based cognitive behavioral self-help designed to increase treatment adherence by minimum therapist contact by email supplementation and short weekly telephone calls. | CG: received no treatment IVR: Intervention modules included information, exercises and interactive quiz that ended with 3–8 essay questions. Pts encouraged to explain the most important sections of the module, provide thought records, describe experience with and outcome of their exposure exercise. For each module, pts required to post at least one online message in an online discussion group about a predetermined topic. Feedback on homework assign given within 24 hrs One weekly telephone call made weekly to each pt to provide positive feedback and to answer questions the pt had about the module. | Computer | Information modules, email, online discussion board | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | IVR vs. CG Liebowitz social anxiety scale Fear/Anxiety Pre treatment score: Mean (SD) 36.0 (+11.7) vs. 34.2 (+10.6) Post treatment score ; Mean (SD) 24.2 (+12.0) vs. 36.1 (+12.3) Main effect Time: F=16.8, (p<0.001), group; F= 3.1 Interaction effect: 32.2 (p<0.001) Effect size Within group: 1.00 vs. - 0.17 Between group: 0.98 Avoidance Pre treatment score: Mean (SD) 35.2 (+12.9) vs. 33.8 (+11.0) Post treatment score ; Mean (SD) 21.6 (+12.8) vs. 33.3 (+11.9) Main effect Time: F= 34.2, (p<0.001), group, F= 3.0 Interaction effect: 29.2 (p<0.001) Effect size Within group: 1.06 vs. 0.04 Between group: 0.95 Social phobia scale (Total score) Pre treatment score: Mean (SD) 36.2 (+15.2) vs. 37.8 (+16.5) Post treatment score ; Mean (SD) 20.0 (+15.0) vs. 37.7 (+16.4) Main effect Time: F= 28.3, (p<0.001), group, F= 6.1, p<0.05 Interaction effect: 27.8, p< 0.001 Effect size Within group: 1.07 vs. 0.01 Between group: 1.13 Social interaction anxiety scale, Total Pre treatment score: Mean (SD) 41.3 (+13.2) vs. 42.9 (+12.1) Post treatment score ; Mean (SD) 27.1 (+11.1) vs. 43.6 (+14.0) Main effect Time: F= 23.1, (p<0.001), group, F= 8.8, p<0.0125 Interaction effect: 28.3 (p<0.001) Effect size Within group: 1.16 vs. - 0.05 Between group: 1.31 Social Phobia screening questionnaire, Total Pre treatment score: Mean (SD) 29.7 (+7.8) vs. 31.4 (+9.4) Post treatment score ; Mean (SD) 20.3 (+9.1) vs. 32.3 (+8.9) Main effect Time: F= 27.7, (p<0.001), group, F= 9.9, p< 0.0125 Interaction effect: 41.2 (p<0.001) Effect size Within group: 1.11 vs. - 0.10 Between group: 1.33 Montgomery Asberg depression rating scale, total score Pre treatment score: Mean (SD) 13.4 (+8.4) vs. 13.5 (+6.0) Post treatment score ; Mean (SD) 8.5 (+5.9) vs. 14.5 (+7.2) Main effect Time: F= 5.7, (p<0.05), group, F= 3.4 Interaction effect: 12.4 (p<0.001) Effect size Within group: 0.69 vs. - 0.15 Between group: 0.92 Beck anxiety inventory, total score Pre treatment score: Mean (SD) 14.5 (+8.1) vs. 15.1 (+8.8) Post treatment score ; Mean (SD) 8.2 (+7.9) vs. 14.5 (+9.0) Main effect Time: F= 15.4, (p<0.001), group, F= 2.8 Interaction effect: 10.2 (p<0.0125) Effect size Within group: 0.79 vs. 0.07 Between group: 0.75 | NR | Quality of life inventory, Summary score Pre treatment score: Mean (SD) 0.7 (±2.0) vs. 0.5 (±1.7) Post treatment score ; Mean (SD) 1.4 (±1.8) vs. 0.7 (±1.8) Main effect Time: F= 9.9, (p<0.0125), group, F= 1.16 Interaction effect: 3.2 Effect size Within group: 0.37 vs. 0.11 Between group: 0.39 | NR | Total randomized= 60, Treatment grp=30 Began other therapy=1 eligible for analysis=29 Did not return completed measures=1 Post treatment assessment= 28 Did not complete follow up=1 Follow up data = 27 Control grp= 30 Began other therapy=1 No computer access=1 Eligible for analysis=28 Post treatment survey= 28 No FU for control grp | NR
Cathala | 2003 | Outpatient dept. at Institute Monstouris | Dept. of Urology, Institute Monstouri | Homes | Cohort | N = 140 | Preliminary study: January–March 2000 November 2000–April 2002 | NR | *Patients with localized prostate cancer treated with radical prostatectomy *Computer in home | NR | NR | NR | PROSTATE CANCER | NR | N = 100% | Mean: 63 Range: 46–70 | NR | Senior executives and professionals: 58% Tradesmen: 12% | NR | NR | NR | NR | NR | English, French | NR | Website | Website to securely house data and answer questions for those with a radical prostatectomy | NR | Website | History of surgery - techniques and complications, video on operation, glossary, access to medical files including discharge, operative and histology, QOL questionnaire, patient/dr. dialogue | NR | NR | NR | NR | NR | NR | NR | 11% had problems accessing site, 14% had tech problems attributed to incorrect PSA data entry or not having the right software to run the video | NR | Satisfied with site sections: 98% Satisfied with medical file: 94% | NR | NR | NR | NR | NR | NR | NR | Older patients used email follow up more than younger ones, email follow up was greater for patients living further from the hospital
Cavan | 2003 | NR | NR | Homes | Cohort | N= 6 | NR | 6 months | NR | NR | NR | Unclear | DIABETES | NR | NR | Mean: 36 Range: 29–61 | NR | NR | NR | Unclear | NR | NR | NR | NR | NR | Diasnet | A structured patient education program which utilizes the DiasNet computer model to display and manipulate patient data. The program used as a training exercise in carbohydrate assessment and insulin dose adjustment to help patients optimize their metabolic control | N=6 Pts asked to enter from home or work PC, blood glucose values, insulin doses and a food diary. The computer model generated the a simulation of the blood glucose concentration for the data collection period. It then suggested alternative insulin doses (regimes), or meal sizes, to reduce risk of hypo and hyperglycemia. Pts entered four days data on three occasions in the first month and then as often as they wished. | Computer | Data entry, simulation of blood glucose concentration, suggestion of alternative medication regimes | NR | Pts attended a one hour training session, which covered accessing the system, data entry and interpretation. | NR | There is a graph showing HbA1c levels but difficult to give precise values, as author has not reported the same. | NR | NR | NR | Pts did not enter any data for several weeks, only one entered data on three consecutive as requested. | All pts found the graphical display and ability to manipulate their data very useful. Qualitative responses of pts given, not listed here | NR | NR | NR | NR | NR | NR | NR | NR | NR
Cawsey | 2000 | NR | Beatson Oncology center, Glasgow | Homes | RCT (more details given in Jones 1999) | N= 525 | NR | NR | NR | Pts receiving palliative treatment, those with no knowledge of their diagnosis, those with only a single treatment planned and those not giving consent to participate | NR | NR | CANCER | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | Personalized information system | Evaluation of a personalized information system for patients with cancer. The system dynamically generates hypertext pages that explain treatment, diseases, measurements etc related to the patient's condition, using information in the patients medial record as the basis for the tailoring | Grp 1: personalized information; access to the system that generated personalized explanation using the medical record, pts received a printout of the dialogue with the system after the session Grp 2: generalized information; access to system with similar look and feel but only contained generalized information, main differences were the opening screen and detailed content of individual screens. Grp 3: combined group; this grp had access to both the above systems, an initial screen provided links to both. Grp 4: leaflets group; grp given opportunity to browse and select from a folder containing a wide range of appropriate leaflets | Computer | General and personalized information | NR | The first 3 grps were invited to carry out a computer consultation at the beginning of their course of radiotherapy in the researcher's office; pts also offered to use a computer again after their first use, but one sited in the waiting room | NR | NR | NR | NR | Small but not significant effect on doctor's assessment of how knowledgeable pts were— with the result that more pts in the general group were viewed as above average, (35% vs. 27%, p=0.19) | NS difference in the average time spent using the computer and only a small difference (p=0.11) in which group used the computer at any time after the first session. Pts receiving personalized information was more likely to use the computer between 3 weeks and 3 months (12/80 vs. 4/155, chi sq=12.8, p<0.001) The majority of the pts used the printouts of their sessions with the computer later at home, 73% of personalized information grp and 59% of general information grp (chi square=3.4, 1 df, p=0.07) Pts in the personal grp were more likely to report using it with their family | NR | Pt views on information given; general vs. personal Was info useful: 76 (60) vs. 51 (70), p=0.16 Did it tell you anything new: 63 (50) vs. 46 (64), p=0.05 Was information relevant: 85 (66) vs. 63 (85), p= 0.004 Find information easily:109 (85) vs. 63 (89), p= 0.41 Feel overwhelmed with info: 37 (29) vs. 17 (23), p=0.41 Was it too technical:18 (14) vs. 6 (8), p=0.23 Was it too limited: 71 (56) vs. 30 (41), p= 0.04 Satisfaction score: 44 (26) vs. 36 (42), p= 0.04 A t test between patient satisfaction scores between the two groups shows that the mean score of 2.33 for the personal group is significantly higher than the mean score of 1.64 for the general group. (t=3.27, 198 df, p=0.001) | NR | NS difference found in the psychological state between the groups as measured by the HADS and MAC questionnaires. NS difference on the doctor's assessment of their anxiety, or of how active/passive they were | NR | NR | NR | 789 pts were eligible for the study 74 excluded and 190 refused to take part in the study (more details in Jones et al 1999) | NR | At 3 months, pts asked if they would prefer unlimited time with their computer for getting information, or 10 mins with a specialist nurse or radiographer. Most preferred latter, but pts using personalized design were slightly more likely to choose time with the computer (32% vs. 20%), (chi square=2.9, 1df, p=0.09)
Chan | 2003 | Pediatric clinic | Honolulu, HI | Homes | Cohort | N= 10 | 6 mos | NR | *Pediatric patients *Ages 6–17 *Persistent asthma *Written informed consent obtained from parents/guardians *Assent obtained from all children over the age of 7 | NR | NR | NR | ASTHMA | NR | Total: 50% Office grp: 80% Virtual: 20% | Mean (SD) 7.6 (±2) | NR | NR | NR | NR | NR | NR | NR | NR | NR | Home monitoring service | Pts used the digital video camera and computer to record peak flow meter readings and their daily use of the MDI or DPI two times a week | Office group: had scheduled office visits to receive asthma education Virtual group: received asthma education via the internet | Home computer system, video camera, microphone, cable to access the internet | Receive asthma education via the internet, record peak flow meter use and values, transmit this data | NR | NR | NR | Asthma Control Days 0–90 Peak flow values (% of personal best) Total: 84.3 Virtual: 82.7 Office: 86.0 Total # unscheduled asthma clinic visits Total: 2 Virtual: 1 Office: 1 % symptom-free days as recorded in diary Total: 75.1 Virtual: 70.8 Office: 80.4 Mean (SD) total symptom-control score Total: 4.5 (±0.5) Virtual: 4.5 (±0.6) Office: 4.4 (±0.4) Mean (SD) # beta-agonist uses in diary Total: 10.8 (±18.0 Virtual: 3.0 (±3.3) Office: 20.5 (±24.9) Total # beta-agonist refills Total: 11 Virtual: 7 Office: 4 Mean (SD) # beta-agonist refills per pt/mo Total: 0.4 (±0.6) Virtual: 0.5 (±0.9) Office: 0.3 (±0.4) Total # short courses of oral corticosteroids Total: 9 Virtual: 6 Office: 3 Mean (SD) # short courses of oral corticosteroids per pt Total: 1.0 (±0.9) Virtual: 1.2 (±1.3) Office: 0.8 (±0.5) Days 91–180 Peak flow values (% of personal best) Total: 91.8 Virtual: 90.3 Office: 93.3 Total # unscheduled asthma clinic visits Total: 3 Virtual: 0 Office: 3 % symptom-free days as recorded in diary Total: 84.3 Virtual: 91.7 Office: 77.0 Mean (SD) total symptom-control score Total: 4.4 (±0.8) Virtual: 4.1 (±0.2) Office: 4.6 (u0.8) Mean (SD) # beta-agonist uses in diary Total: 11.3 (±19.7) Virtual: 1.3 (±1.5) Office: 21.3 (u25.8) Total # beta-agonist refills Total: 10 Virtual: 4 Office: 6 Mean (SD) # beta-agonist refills per pt/mo Total: 0.3 (±0.4) Virtual: 0.3 (±0.3) Office: 0.4 (±0.6) Total # short courses of oral corticosteroids Total: 6 Virtual: 2 Office: 4 Mean (SD) # short courses of oral corticosteroids per pt Total: 0.6 (±0.7) Virtual: 0.4 (±0.6) Office: 0.8 (±0.8) | Therapeutic Adherence Days 0–90 Virtual vs. Office vs. Total Total # corticosteroid inhalers refilled: 8 vs. 16 vs. 24 Mean (SD) # corticosteroid inhalers per patient per mo 0.5 (±0.5) vs. 1.1 (±0.6) vs. 08. (±0.6) Total # videos of inhaler use sent 84 vs. 109 vs. 193 Mean (SD) # videos of inhaler use submitted per person 16.8 (±3.4) vs. 21.3 (±6.7) vs. 19.3 (±5.6) Adherence to submission of videos of inhaler use (%) 70.0 vs. 90.8 vs. 80.4 DPI or MDI plus space technique score (%) 87.2 vs. 87.3 vs. 87.3 Days 91–180 Virtual vs. Office vs. Total Total # corticosteroid inhalers refilled: 6 vs. 8 vs. 14 Mean (SD) # corticosteroid inhalers per patient per mo 04. (±0.3) vs. 0.5 (±0.4) vs. 0.5 (±0.3) Total # videos of inhaler use sent 65 vs. 63 vs. 128 Mean (SD) # videos of inhaler use submitted per person 13.0 (±5.7) vs. 12.6 (±11.5) vs. 12.8 (±8.6) Adherence to submission of videos of inhaler use (%) 54.2 vs. 52.5 vs. 53.3 DPI or MDI plus spacer technique score (%) 95.2 vs. 93. 5 vs. 94.3 | NR | Asthma Knowledge Test and Survey Results, Mean (SD) Virtual vs. Office vs. Total Knowledge test score (%) Before Study 82.0 (±8.8) vs. 77.0 (±5.2) vs. 79.8 (±7.5) After Study 84.8 (±7.6) vs. 8.3 (±5.5) vs. 84.0 (±6.6) | Diagnostic Adherence Virtual vs. Office vs. Total Days 0–90 Total # asthma diary entries 119 vs. 293 vs. 412 Mean (SD) # asthma diary entries per patient 23.8 (±23.8) vs. 58.6 (±39.4) vs. 41.2 (±35.7) Asthma diary adherence (%) 18.7 vs. 65.1 vs. 41.9 Total # videos of peak flow meter use submitted 83 vs. 111 vs. 194 Mean (SD) # videos of peak flow meter use submitted per patient 16.6 (±3.2) vs. 22.2 (±7.5) vs. 19.4 (±6.2) Adherence to submission of videos of peak flow meter use (%) 69.2 vs. 92.5 vs. 80.8 Peak flow meter technique score (%) 99.7 vs. 99.2 vs. 99.5 Days 91–180 Virtual vs. Office vs. Total Total # asthma diary entries 30 vs. 88 vs. 118 Mean (SD) # asthma diary entries per patient 6.0 (±7.9) vs. 17.6 (±22.3) vs. 11.8 (±16.9) Asthma diary adherence (%) 6.7 vs. 19.6 vs. 13.1 Total # videos of peak flow meter use submitted 54 vs. 61 vs. 115 Mean (SD) # videos of peak flow meter use submitted per patient 10.8 (+6.1) vs. 12.2 (±10.8) vs. 11.5 (±8.3) Adherence to submission of videos of peak flow meter use (%) 45.0 vs. 50.8 vs. 47.9 Peak flow meter technique score (%) 99.3 vs. 99.9 vs. 99.6 | NR | Virtual vs. Office vs. Total Satisfaction survey score 4.0 (±0.3) vs. 4.2 (±0.6) vs. 4.1 (±0.4) Satisfaction with electronic checks 3.8 (±0.8) vs. 4.3 (±1.0) vs. 4.0 (±0.9) | NR | NR | NR | Virtual vs. Office vs. Total QoL Score Before Study Caregiver 5.6 (±1.2) vs. 6.4 (±0.7) vs. 6.0 (±1.0) Patient 6.6 (±0.4) vs. 6.5 (±0.7) vs. 6.5 (±0.5) After study Caregiver 6.2 (±1.0) vs. 6.4 (±0.6) vs. 6.3 (±0.8) Patient 6.6 (±0.2) vs. 6.6 (+0.6) vs. 6.6 (±0.4) | NR | NR | NR | NR
Chen | 2006 | NR | Senior High school students | Homes | Non-Random Group | Total= 77 Grp 1 (auricular acupressure+ internet program): 38 Grp 2 (auricular acupressure only): 39 | NR | NR | NR | NR | NR | NR | SMOKING | NR | Grp 1 vs. Grp 2: 100% vs. 87.2% | NR | NR | NR | High school students | NR | Grp 1 vs. Grp 2 Using antioxidiser: 0% vs. 10.3% Having part time work: 10.5% vs. 20.5% Experiencing smoking cessation: 57.9% vs. 79.5% Having family member who is smoking: 65.8% vs. 69.2% | NR | NR | NR | NR | Smoking cessation program | Comparing effects of auricular acupressure with or without an internet assisted program on smoking cessation and self efficacy of adolescents | Grp 1: received 4 weeks of auricular acupressure plus an internet smoking cessation program Grp 2: received only auricular acupressure Auricular acupressure: five common points used, shenmen, lung, mouth, stomach and endocrine points, seed embedding method used, pts asked to press each point for at least a minute, 3–5 times/day for 4 weeks, adhesive patch with the ear seed renewed weekly. Internet assisted smoking cessation program: website composed of interactive pages with the following units; a) Impact of smoking (smoking and health, second hand smoking, difficulty of quitting and legal regulation; b) Auricular acupressure for smoking cessation (theory, research findings, withdrawal symptoms and treatments and practice of auricular acupressure); c) critical issues in smoking cessation; d) online questionnaire; e) professional counseling (interactive channel between smokers and professionals); f) discussion forum; g) hot topics; h) hyperlinked websites | Computers | Forums, counseling, education, hyperlinked website surfing | NR | NR | NR | Mean serum cotinine level (SD), Grp 1 vs. Grp 2: Before intervention: 346.77 ng/ml (142.51) vs. 376.06 ng/ml (169.71) After intervention: 342.29 ng/ml (182.70) vs. 379.73 ng/ml (187.68) In terms of quitting rate-levels under 100 ng/ml (Grp 1vs Grp2): 6/38 (15.78%) vs. 1/39 (2.56%) For the degree of nicotine dependence Before intervention, Grp 1 vs. Grp 2 Low: 24 (63.2%) vs. 30 (76.9%) Medium: 10 (26.3%) vs. 7 (17.9%) High: 4 (10%) vs. 2 (5.1%) After intervention, grp 1 vs. grp 2 Low: 31 (81.6%) vs. 31 (79.5%) Medium: 6 (15.8%) vs. 5 (12.8%) High: 1 (2.6%) vs. 3 (7.7%) Group 1 showed a statistically significant difference of nicotine dependence before and after intervention (z= - 2.81, p< 0.01) Grp 2 did not show any significant difference (z= - 0.47, p > 0.05) | NR | NR | NR | NR | NR | Usefulness of website, Mean (SD) Overall usefulness of website: 5.02 (±1.49) Discussion forum: 5.53 (±1.47) Auricular acupressure for smoking cessation: 5.15 (±1.46) Impact of smoking: 4.98 (±1.37) Critical issues in smoking cessation: 4.82 (±1.50) Hot topics: 4.76 (±1.72) Hyperlinked websites: 4.66 (±1.61) Professional counseling: 4.64 (±1.39) Online questionnaire: 4.51 (±1.60) | NR | Self efficacy, M (SD), pretest vs. posttest Grp 1: 45.80 (±15.14) vs. 58.57 (±15.67), t= 5.77, p < 0.001 Grp 2: 43.47 (±14.88) vs. 48.97 (±12.54), t= 2.32, p< 0.05 | NR | NR | NR | NR | NR | NR
Cho | 2006 | NR | Kang nam St Mary's hospital diabetes center | Homes | RCT | N= 40 CG: 40 IVR: 40 | February 2002–August 2004 | 30 months | *Age ≥ 30 yrs *Followed up for more than 6 months in the clinic | Disabling conditions or disease like heart failure, hepatic dysfunction, a creatinine level > 0.133 mmol/l, severe complications of diabetes, or treatment with an intensified insulin regimen. Also people who did not have internet access in their homes or offices, did not know how to use the internet, or did not wish to participate in the study were excluded. Pts having history of participating in other programs that provided similar information or if they received diabetes management education from any other website other than the study website were excluded. | NR | NR | TYPE 2 DIABETES | NR | CG: 57.5% IG: 65% | Mean (SD) CG: 54.6 (±8.6) IG: 51.3 (±9.1) | NR | NR | NR | NR | Mean (SD) CG vs. IG Diabetes duration in yrs: 6.9 (±5.7) vs. 6.7 (±5.3), p=0.868 Hypertension: 13 (±32.5) vs. 11 (±27.5), p=0.808 BMI (kg/m2): 23.8 (±2.8) vs. 22.8 (±2.6), p=0.139 SBP (mmHg): 128.5 (±16.1) vs. 121.3 (±16.5), p= 0.070 DBP (mmHg): 77.2 (±9.1) vs. 74.0 (±11.6), p= 0.187 Glucose control methods CG vs. IG Lifestyle modifications: 3 vs. 4 Oral medication only: 30 vs. 25 Oral + Insulin: 3 vs. 5 Insulin only: 4 vs. 6 | NR | NR | NR | NR | Internet Based Glucose Monitoring System (IBGMS) | Internet based system for blood glucose monitoring with additional information such as use of current medication, blood pressure and weight with appropriate recommendations provided by the study team | IG: Pts logged on to biodang.com and uploaded glucose levels on a blood glucose board on the online chart. Additional information on the use of current medication, blood pressure and weight were uploaded. Pts also recorded changes in lifestyle and any questions or detailed information that the pt wished to discuss. The clinical instructors in the team monitored the system and sent appropriate recommendations to each pt every 2 weeks. Every 3 mos, pts had a face to face interview with their physician and provided a blood sample for follow up lab testing. CG: Pts used a conventional note keeping record system. They were given the clinic's usual recommendations about medications, dosage and lifestyle modification from the same endocrinologists who met with the IG | Computer | Uploading glucose levels, e mail communications. | NR | Pts were taught how to use the system | NR | Mean (SD): CG vs. IG FBG (mmol/l) ; Baseline: 7.67 (+2.8) vs. 8.07 (+3.36), p= 0.526 15 months: 7.99 (+1.85) vs. 8.96 (+2.61) 30 months: 7.87 (+1.83) vs. 8.51 (+2.68) A1C (%) Baseline: 7.5 (+1.3) vs. 7.7 (+1.5), p= 0.457 15 months: 7.4 (+1.3) vs. 6.9 (+1.1) 30 months: 7.4 (+1.3) vs. 6.7 (+0.9) Total Cholesterol (mmol/l) Baseline: 4.8 (+0.9) vs. 4.64 (+0.8), p=0.403 15 months: 4.27 (+0.83) vs. 4.49 (+0.72) 30 months: 4.49 (+0.76) vs. 4.5 (+0.67) Triglyceride (mmol/l) Baseline: 1.68 (+1.22) vs. 1.24 (+0.8), p= 0.062 15 months:1.5 (+0.95) vs. 1.66 (+1.29) 30 months: 1.28 (+0.75) vs. 1.16 (+0.73) HDL Cholesterol (mmol/l) Baseline: 1.25 (+0.38) vs. 1.29 (+0.32), p= 0.627 15 months: 1.25 (+0.32) vs. 1.22 (+0.28) 30 months: 1.26 (+0.34) vs. 1.37 (+0.36) BUN (mg/dl) Baseline: 15.2 (+3.8) vs. 14.3 (+3.4), p= 0.285 15 months:15.7 (+4.1) vs. 15.6 (+3.4) 30 months: 16.2 (+3.7) vs. 15.9 (+4.5) Creatinine (mg/dl) Baseline: 0.93 (+0.18) vs. 0.89 (+0.17), p=0.351 15 months: 0.9 (+0.2) vs. 0.9 (+0.2) 30 months: 0.9 (+0.2) vs. 0.9 (+0.2) AST (units/l) Baseline: 23.9 (+14.4) vs. 19.7 (+15.4), p= 0.123 15 months: 23 (+8.5) vs. 21.8 (+11.9) 30 months: 22.5 (+7.4) vs. 20.7 (+7.6) ALT (units/l) Baseline: 25.3 (+14.5) vs. 22.5 (+15.4), p= 0.404 15 months: 28.6 (+13.9) vs. 24.4 (+13.6) 30 months: 27.3 (+10.8) vs. 25.2 (+12.9) Na (mmol/l) Baseline: 140 (+2.6) vs. 4.25 (+0.4), p= 0.825 15 months: 141.5 (+3.4) vs. 140.8 (+2.5) 30 months: 142.1 (+4.1) vs. 140.6 (+2.6) K (mmol/l) Baseline: 4.18 (+0.36), p= 0.455 15 months: 4.3 (+0.4) vs. 4.4 (+0.4) 30 months: 4.3 (+0.4) vs. 4.4 (+0.4) | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | Graphs of the long term results given There is a table of staff recommendations and patient reports given, not listed here
Christensen | 2004 | NR | NR | Homes | RCT | N= 525 Bluepages (Grp 1): 166 Moodgym (Grp 2): 182 Control (Grp 3): 178 | August 2002–May 2003 | 6 weeks | *Access to internet *Scores of 22 or above on the Kesler psychological distress scale *Not receiving clinical care from either a psychologist or a psychiatrist | NR | NR | NR | DEPRESSION | NR | Bluepages: 31% MoodGym: 25% Control: 30% | Bluepages: 37.25 (±9.4) MoodGym: 35.85 (±9.5) Control: 36.29 (±9.3) | NR | NR | Years (SD) spent in education Bluepages: 15.0 (±2.4) MoodGym: 14.6 (±2.4) Control: 14.4 (±2.3) | NR | Marital status (%); Bluepage vs. Moodgym vs. Control Married/cohabiting: 61 vs. 54 vs. 56 Divorced/separated: 15 vs. 14 vs. 14 Never married: 30 vs. 31 vs. 36 Mean score (SD) on Kessler psychological distress scale Bluepage vs. Moodgym vs. Control 17.5 (±4.9) vs. 17.9 (±5.0) vs. 18.0 (±5.7) Info on intervention preference, mean score on center for epidemiological studies depression scale given, not listed here | NR | NR | NR | Blue page and MoodGym | Blue page and MoodGym | Blue page: information about depression with evidence based information at 8th grade reading level from the site http://bluepages.anu.edu.au MoodGym: offered cognitive behavioral therapy for the prevention of depression from site http://moodgym.anu.edu.au | Bluepage (Grp 1): website available freely in world wide web, pts given a login identification number and directed each week to one of the five sections of the website with an overview at 6 weeks, post intervention questionnaire at 6 weeks. MoodGym (Grp 2): pts given a login identification number and undertook online assessments, MoodGym consisted of five interactive modules which were made available sequentially weekly; pts revised all aspects of the program in the sixth week, post intervention questionnaire at 6 weeks. Control Grp (Grp 3): Pts phoned weekly by interviewers to discuss lifestyle and environmental factors influencing depression.(Topics included education and hobbies, social, financial and family roles, work habits and stress, physical health, medications and pain, nutrition and alcohol. | Computer | Education, cognitive behavioral therapy (online assessments) | Interviewers received instruction booklets providing timetables for tracking phone calls and verbatim instructions. | Pts sent detailed guidelines outlining navigation and weekly assignments for MoodGym or Bluepages | NR | NR | NR | NR | Intention to treat (n=525) Medical Literacy Bluepages vs. MoodGym vs. Control: -0.6 (+0.7) vs. -0.1 (+0.5) vs. -0.1 (+0.5) Difference (95% CI) Bluepages vs. MoodGym: -0.5 (-0.7 to -0.4) (S) MoodGym vs. Control: 0.0 (-0.1 to 0.2) Bluepages vs. Control: -0.5 (-0.6 to -0.3) (S) Psychological Literacy Bluepages vs. MoodGym vs. Control: -0.7 (+1.1) vs. -0.5 (+1.0) vs. - 0.0 (+0.9) Difference (95% CI) Bluepages vs. MoodGym: -0.3 (-0.5 to 0.0) (S) MoodGym vs. Control: -0.4 (-0.7 to -0.2) (S) Bluepages vs. Control: -0.7 (-1.0 to -0.4) (S) Lifestyle Literacy Bluepages vs. MoodGym vs. Control: -0.6 (+0.9) vs. -0.0 (+0.5) vs. 0.1 (+0.8) Difference (95% CI) Bluepages vs. MoodGym: -0.5 (-0.7 to -0.4) (S) MoodGym vs. Control: -0.1 (-0.3 to 0.0) Bluepages vs. Control: -0.7 (-0.9 to -0.5) Cognitive Behavior Therapy Literacy Bluepages vs. MoodGym vs. Control: -1.1 (+2.0) vs. -2.0 (+2.4) vs. 0.1 (+1.6) Difference (95% CI) Bluepages vs. MoodGym: 0.9 (0.4 to 1.4) (S) MoodGym vs. Control: -2.1 (-2.6 to -1.6) Bluepages vs. Control: -1. 2 (-1.7 to -0.7) Completers (n=414) Medical literacy Bluepages vs. MoodGym vs. Control: -0.8 (+0.7) vs. -0.1 (+0.5) vs. -0.2 (+0.5) Difference (95% CI) Bluepages vs. MoodGym: -0.6 (-0.8 to -0.5), (S) MoodGym vs. Control: 0.1 (-0.1 to 0.3) Bluepages vs. Control: -0.6 (-0.7 to -0.4) (S) Psychological Literacy Bluepages vs. MoodGym vs. Control: -0.9 (+1.1) vs. -0.7 (+1.1) vs. -0.0 (+1.0) Difference (95% CI) Bluepages vs. MoodGym: - 0.2 (-0.6 to 0.1) MoodGym vs. Control: -0.6 (-0.9 to -0.3) (S) Bluepages vs. Control: - 0.9 (-1.2 to -0.6) (S) Lifestyle Literacy Bluepages vs. MoodGym vs. Control: -0.7 (+0.9) vs. -0.0 (+0.6) vs. 0.1 (+0.7) Difference (95% CI) Bluepages vs. MoodGym: -0.7 (-0.9 to -0.5) (S) MoodGym vs. Control: -0.1 (-0.4 to 0.1) Bluepages vs. control: -0.8 (-1.0 to -0.6) (S) Cognitive Behavior Therapy Literacy Bluepages vs. MoodGym vs. Control: - 1.4 (+2.2) vs. - 2.8 (+2.4) vs. 0.1 (+1.7) Difference (95% CI) Bluepages vs. MoodGym: 1.4 (0.8 to 2.0) (S) MoodGym vs. Control: -2.8 (-3.4 to -2.2) (S) Bluepages vs. control: -1.4 (-2.0 to -0.9) Completers 16 or more on center for epidemiological studies depression scale (n= 369) Medical Literacy Bluepages vs. MoodGym vs. Control: -0.7 (+0.7) vs. -0.1 (+0.5) vs. -0.1 (+0.5) Difference (95% CI) Bluepages vs. MoodGym: -0.6 (-0.8 to -0.4) (S) MoodGym vs. Control: 0.1 (- 0.1 to 0.2) Bluepages vs. Control: -0.5 (-0.7 to -0.3) (S) Psychological Literacy Bluepages vs. MoodGym vs. Control: - 0.8 (+1.0) vs. - 0.4 (+1.0) vs. - 0.1 (+1.0) Difference (95% CI) Bluepages vs. MoodGym: -0.4 (- 7.0 to -1.0) MoodGym vs. Control: -0.3 (-0.6 to 0.0) Bluepages vs. Control: -0.7 (-1.0 to -0.4) (S) Lifestyle Literacy Bluepages vs. MoodGym vs. Control: -0.6 (+0.8) vs. -0.1 (+0.5) vs. 0.1 (+0.6) Difference (95% CI) Bluepages vs. MoodGym: -0.5 (-0.7 to -0.3) (S) MoodGym vs. Control: -0.2 (-0.4 to 0.0) Bluepages vs. Control: -0.7 (-0.9 to -0.5) (S) Cognitive Behavior Therapy Literacy Bluepages vs. MoodGym vs. Control: -1.1 (+1.9) vs. -1.8 (+2.1) vs. -0.0 (+1.6) Difference (95% CI) Bluepages vs. MoodGym: 0.8 (0.2 to 1.4) (S) MoodGym vs. Control: - 1.8 (-2.4 to -1.3) (S) Bluepages vs. Control: -1.0 (-1.6 to -0.4) | Bluepage: Site visited an avg of 4.49 (SD= 1.35, n=113) with an average of 67.2 (23.9) hits MoodGYM: pts completed half of 29 exercises (14.8, 9.7) | NR | The author states that both the sites were acceptable to pts, with dropout rates of 25% and 15% (these rates are remarkably low in comparison with other interventions) | Intention to treat (n=525) Center for epidemiological studies depression scale, Mean (SD) Bluepages vs. MoodGym vs. Control: 3.9 (±9.1) vs. 4.2 (±9.1) vs. 1.0 (±8.4) Difference (95% CI) Bluepages vs. MoodGym: -0.3 (-2.6 to 2.0) MoodGym vs. Control: 3.2 (0.9 to 5.4) (significant at 0.05 level-S) Bluepages vs. Control: 2.9 (0.6 to 5.2) (S) Automatic thoughts questionnaire Bluepages vs. MoodGym vs. Control= 6.4 (±18.1) vs. 9.3 (±16.9) vs. 3.1 (±15.8) Difference (95% CI) Bluepages vs. MoodGym: 2.8 (-7.2 to 1.5) MoodGym vs. Control: 6.1 (1.9 to 10.4) (S) Bluepages vs. Control: 3.3 (- 1.1 to 7.7) Completers (n=414) Center for epidemiological studies depression scale, Mean (SD) Bluepages vs. MoodGym vs. Control: 4.9 (±9.8) vs. 5.8 (±9.9) vs. 1.2 (±8.9) Difference (95% CI) Bluepages vs. MoodGym: -0.9 (-3.7 to 2.0) MoodGym vs. Control: 4.5 (1.8 to 7.3) (S) Bluepages vs. Control: 3.6 (1.0 to 6.3) (S) Automatic thoughts questionnaire Bluepages vs. MoodGym vs. Control: 7.9 (±19.5) vs. 12.0 (±17.4) vs. 3.6 (±16.7) Difference (95% CI) Bluepages vs. MoodGym: -4.1 (-9.5 to 1.3) (S) MoodGym vs. Control: 8.4 (3.2 to 13.6) (S) Bluepages vs. Control: 4.3 (-0.8 to 9.3) Completers 16 or more on center for epidemiological depression scale (n= 369) Center for epidemiological studies depression scale, Mean (SD) Bluepages vs. MoodGym vs. Control: 5.9 (±9.3) vs. 5.7 (±9.8) vs. 2.1 (±8.2) Difference (95% CI) Bluepages vs. MoodGym: 0.2 (-2.6 to 3.0) MoodGym vs. Control: 3.6 (0.8 to 6.3) (S) Bluepages vs. Control: 3.8 (0.9 to 6.6) (S) Automatic thoughts questionnaire Bluepages vs. MoodGym vs. Control: 10.4 (±20.0) vs. 16.2 (±20.0) vs. 4.5 (±18.3) Difference (95% CI) Bluepages vs. MoodGym: -5.9 (-12.4 to 0.9) MoodGym vs. Control: 11.7 (5.1 to 18.3) (S) Bluepages vs. Control: 5.9 (-0.6 to 12.4) | NR | NR | NR | NR | MoodGYM: 25% Bluepage: 15% Bluepages Assigned= 165 Total dropouts= 25 (Too busy=5, not contactable=2, trouble with internet= 1, ill=1, didn't like=1, incorrectly included=1, no reason given=4) MoodGym Assigned= 182 Total dropout= 46 (No reason given=12, not contactable=10, too busy=7, family reasons=3, didn't like it=6, trouble with internet=5, other=3) Control Assigned= 178 Total dropout=19 (no reason given=14, lost interest=1, family problem=1, too busy=1, not contactable= 1, ill=1) | NR | NS
Cross | 2007 | University of Maryland IBD program and gastroenterology clinic at VA in Baltimore | Maryland | Homes | Cohort | N=25 | 2004-2005 | 6 months | *Diagnosable IBD *Comprehend simple instructions in English *Have telephone at home *Ages ≥ 18 years | Posessing other types of colitis (infectious, ischemic, microscopic), no telephone at home, uncontrolled medical or psychiatric disease,had had surgical ostomy, had undergone IBD surgery in the past 6 months, had had a previous colectomy and ileoanal anastomosis, were pregnant, or were less than 18 years of age | NR | NR | IBD | NR | 52% | 43.1 ± 15.3 | Caucasian: 76% Hispanic: 8% African American: 16% | NR | Years (SD) spent in education Bluepages: 15.0 (±2.4) MoodGym: 14.6 (±2.4) Control: 14.4 (±2.3) | NR | Type of IBD Ulcerative Colitis: 60% Crohn's Disease: 32% Indeterminate Colitis: 8% Disease severity in previous months None: 16% Mild: 24% Moderate: 44% Severe: 16% Employment Full-time: 56% Part-time: 16% Student: 8% None: 20% Medical Therapy Aminosalicylates: 40% Antibiotis: 20% Steroids: 52% Immunomodulators: 32% Infliximab: 20% Cyclosporine: 4% Internet Use Once a day: 76% Once a week: 8% Once a month or less: 8% Never: 8% Computer Use at Home Once a day: 52% Once a week: 24% Once a month or less: 16% Never: 8% | NR | NR | English | NR | Home Telemanagement System (HAT) | Laptop connected to an electronic scale: desgined for pt self-test and symptom diary recording along with medication side effect recording and automated feedback (tailored to the symptoms/side effects of each pt) | All pts received their normal IBD care along with HAT | Laptop and a Scale | Education, data input, data collection, tailored feedback | NR | 30–40 minute instruction session at home | Regular IBD care | NR | NR | NR | Pre-Intervention Very limited: 32% Good: 64% Excellent: 4% CCKNOW Scores Baseline vs. 6 months 12 ± 4.4 vs. 9.2 ± 5.3 | Adherence: overall weekly adherence with self-tests was 91% ±11 with only 3 pts (12%) completing less than 80% the self-tests during the 6 month period | 91% thought the self-testing was not compolicated and that it took very little time 86% said that the testing did not interefere with their normal activities 64% said they could do the self-testing more than once a week | 81% said that the initial training session was sufficient to use HAT 9% thought that it was too limiting to use HAT 91% of pts would consider using HAT in the future 90% of pts were happy with help they received from HAT at 6 mos vs. 70% initially | Baseline vs. 6 months HBI 3.8 ± 4.3 vs 2.2 ±3.6 p = 0.09 Sedimentation Rate 25.7 ± 34.4 vs. 16.1 ± 17.9 p = 0.06 C-reactive Protein 11.3 ± 25.9 vs. 3 ± 4 p = 0.13 86% of pts reported receiving excellent care at 6 mos, vs. 65% at baseline 57% of pts had their needs met at baseline, 71% after implementaiton of HAT | NR | NR | SIBDQ Questionnaire Scores Baseline vs. 6 months 49.2 ± 15.1 vs. 55.6 ± 14.5 p = 0.06 | NR | N=34 5 did not comply with installation of HAT in home 2 pts did not have telphone at home 1 pt withdrew after 1st month 1 pt had extended hospital stay | NR | NS
Cruz-Correia | 2007 | Outpatient clinic | Immunoallergy clinic | Homes | Randomized cross-over study | N = 21 Internet first: 7 Paper first: 12 | NR | 2 mos | *Age 16 to 65 *Diagnosis of asthma for 6+ months *Use inhaled budesonide/formoterol *Pre-bronchodilator FEV1 >50% predicted | Severe psychiatric, neurological, oncologic or immunologic disease. Unable to access Internet during study period. | NR | NR | ASTHMA | NR | N = 29% | Mean: 29 | NR | NR | NR | NR | NR | NR | NR | NR | NR | P'ASMA | Web-based monitoring and decision support tool, tailored action plan, for patients and physician, vs. paper-based monitoring | Paper ® Internet (4 wks each) Internet ® Paper (4 wks each) | Peak flow and symptom diary | NR | NR | Subjects given instruction on instruments and peak-flow monitoring during each 4-week phase of the study | NR | NR | NR | NR | NR | Median time to complete diaries was 3 minutes for paper and Internet (p=.675) Median time to complete peak flow monitoring was 2 minutes (same for both) | Paper vs. Internet vs. Piko-1 (peak flow): Easy to record data: 93% vs. 93% vs. 93% Easy to view data: 81% vs. 93% vs. 67% Like to use it: 80% vs. 93% vs. 100% Takes too long to use: 31% vs. 33% vs. 37% | NR | NR | NR | Mean % adherence to self-monitoring Piko-1 during paper: 45% Piko-1 during Internet: 46% Paper diary: 92% Internet diary: 41% | NR | NR | NR | NR | Paper vs. Internet vs. Piko1 (peak flow): Easy to forget: 44% vs. 47% vs. 40% It may be useful: 87% vs. 100% vs. 93% It may help improve asthma control a lot: 50% vs. 73% vs. 50% It may help improve treatment adherence a lot: 53% vs. 64% vs. 58%
Delgado | 2003 | NR (author says that patients attending the university heart failure clinic but does not give any other details) | Heart failure clinic at Toronto General hospital | Homes | Cohort | N=16 | NR | 3 months | *Confirmed diagnosis of heart failure *Internet access at home or workplace *Pts who did not have access to the internet but who had a caregiver who could access the internet were also invited to participate | Expected survival rate of less than 6 months based on the patient's clinical status and prognostic functional tests (e.g. cardiopulmonary tests ordered by the cardiologist) | NR | Unclear | HEART FAILURE | NR | N = 10 pts (62.5%) | Mean (SD): 53.3 (±12.5) Range: 32–83 | NR | NR | NR | Unclear/NR | Ishaemic disease: 5 pts Idiopathic dilated cardiomyopathy: 9 pts Other causes: 2 pts NYHA classification Class 2: 7 pts Class 3: 9 pts Medication profile ACEI: 14 pts (87.5%) Beta blockers: 13 pts (81.2%) Spironolactone: 10 pts (62.5%) Digoxin: 13 pts (81.2%) Furosemide: 14 pts (87.5%) ARB: 3 pts (18.7%) Hydralazine/nitrates: 1 pt (0.6%) | NR | NR | NR | NR | www.heartfunction.com | Internet communication website was designed to be an informative resource for the patient and a daily communication method between patients and heart failure clinic at Toronto general hospital. | 16 patients recruited in the cohort study. The website allowed for quick trending of weights, checking of medication, tracking goals of therapy and easy communication of non urgent cases. Pt were asked not to use the system for urgent communications. The website provided updated information of the most relevant clinical trials in heart failure, updates made every 3 months to the homepage, facilitated links to sites like AHA, WHO. Pts instructed to enter their first morning weight, heart rate and blood pressure and any specific comments or questions, reply sent through the system by research nurse, responses included increasing or decreasing the dose of diuretic, obtain blood work, info about test results, etc. Pt education reinforced, salt restriction, dietary counseling, exercise, weight and symptom management | Computer | Daily logs of weight, communication with research nurse, education, links to other sites | NR | NR | NR | NR | NR | NR | NR | For pts who completed the study questionnaire within 3 months, the average of logins was 73 Drop off in frequency of site hits by a small group of patients over time, but majority continued usage over long periods (over 1 year) | NR | Questionnaire on patient satisfaction, Mean score results The links at the site were useful: 4.37 I was able to enter information easily: 5.0 I would reliably receive a response from the clinic: 4.56 I found the clinic website useful: 4.62 Communication using the website improved my quality of care: 4.12 | NR | NR | NR | Mean MLHFQ score Baseline: 59.75 (±1.5) 3 months: 49.87 (±1.3) 3 month scores vs. baseline scores Relationship with friends and family 3.062 vs. 2.06,p =0.03 Working around the house and yard 3.68 vs. 2.81, p=0.008 Side effects of medication 2.81 vs. 1.93, p=0.048 | NR | NR | NR | Qualitative responses for patient satisfaction given, not listed here
Durso | 2003 | NR | Physician clinic (The author's practice) | Homes | Cohort | N=10 | NR | 3 months | Not Specified *Type2 diabetes pts *Over 60 yrs of age *Independent in self-care *Able to use the phone | NR | NR | Unclear | TYPE 2 DIABETES | NR | N = 3 (42.86%) | Mean (SD): 78.43 (±9.91) | NR | NR | 6 pts had some college or higher level of education | Unclear | Living alone in continuing care retirement community: 2 pts Living with son: 1 pt Living with spouses: 4 pts Medication Taking 9 or more medicines/day: 4 pts Managed with insulin: 3 pts Treated with oral diabetics- others Cellular telephone used by 1 pt before study For the study Cellular telephone used by 3 pts Home phones used by 2 pts Used both - 2 pts | NR | NR | NR | NR | personal diabetes management system (PDMS) | Web based interface into the automated telephone call system used to look into older patient's ability to use the PDMS and its impact on diabetes health behaviors and patient and provider communications | 10 patients recruited. At times predetermined by patients and provider, the PDMS prompts patients with interactive recorded human voice messages, these include performing self care activities (e.g. check feet, check blood glucose, take medication), calling the provider for medical advice, providing health education, recording personal health data. Messages customized to meet individual needs. Pts record data by entering values on the key pad. data then transmitted to the secure web site and reviewed by health care provider at his/her discretion. | Telephone | Data logs, customized reminders, performing self care activities, providing health education | NR | Each pts was provided with individualized diabetes education. Pts also given American Diabetes Association (ADA) book Diabetes A to Z. The nurse practitioner taught each pt how to use the cellular phone to receive messages and record glucose values and weight. The PDMS prompted pts to call nurse practitioner when pt experienced diabetic symptoms, medication side effects or any problems with the care plan. | NR | Glycosylated hemoglobin (%) subject - Before vs. after 1001 - 8.6 vs. 7.3 1002- 7.4 vs. 7.0 1004- 6.7 vs. 6.8 1005- 6.0 vs. 6.1 1007- 8.6 vs. 7.6 1008- 7.8 vs. 8.0 1011- 8.3 vs. 5.9 BMI subject - Before vs. After 1001- 30 vs. 32 1002- 24 vs. 23 1004- 33 vs. 33 1005- 29 vs. 28 1007- 29 vs. 27 1008- 28 vs. 29 1011- 35 vs. 33 | NR | NR | Diabetes Knowledge test scores (%) Subject- Before vs. After 1001: 86 vs. 86 1002: 79 vs. 100 1004: 57 vs. 86 1005: 71 vs. 71 1007: 79 vs. 100 1008: 79 vs. 71 1011: 64 vs. 57 | NR | PDMS study usability questions (1–5 scale, 5 is the best), Mean (SD) Convenience of cellular phones: 3.71 (±1.7) Convenience of home phones: 4.17 (±1.60) Quality of voice on phone: 4.71 (±0.76) Your ability to understand message: 4.71 (±0.76) Ease of cell phone use: 2.57 (±1.40) Ease of home phone use: 4.33 (±1.63) Ease of recording glucose, weight, and exercise: 3.86 (±1.46) Value in management of diabetes: 4.28 (±0.95) Aid to communication with health provider: 4.28 (±1.50) | NR | NR | NR | Frequency: % (n) (Before) vs. % (n) (After) Activity Never: 42.9% (3) vs. 0 1–2 X week: 14.3%(1) vs. 14.3% (1) 3–4 X week: 14.3% (1) vs. 28.6% (2) 5–6 X week: 28.6% (2) vs. 14.3% (1) Everyday: 0 vs. 42.9% (3) Monitor glucose Never: 28.6% (2) vs. 14.3% (1) 4–6 X week: 14.3% (1) vs. 14.3% (1) Once/day: 28.6% (2) vs. 28.6% (2) More than once/day: 28.6%(2) vs. 42.9% (3) Miss medication Never: 85% (6) vs. 85% (6) 1–2 X month: 0 vs. 14.3 % (1) 1–3 X week: 14.3% (1) vs. 0 Check feet Daily: 100 % (7) vs. 100% (7) Symptoms of hypoglycemia Never: 42.9% (3) vs. 14.3% (1) 1–2 X month: 57.1 % (4) vs. 71.4 % (5) 1–3 X week: 0 vs. 14.3 % (1) Symptoms of hyperglycemia Never: 57.1% (4) vs. 42.9% (3) 1–2 X month: 14.3 % (1) vs. 28.6% (2) 1–3 X week: 0 vs. 14.3 % (1) Everyday: 28.6% (2) vs. 14.3 % (1) | NR | NR | 3 did not complete the study due to acute illness and hospitalization | NR | Qualitative response in the form of summary of participants comments given, not listed here
Earnest | 2004 | Waiting room of clinic | CHF clinic at U of Colorado Hospital at Denver | Homes | RCT | N = 107 Grp 1: 54 Grp 2: 53 | January– December 2002 | 12 mos | *Followed up in the clinic, *Spoke English *18+ yrs old *Have used a web browser (not necessary to have home internet) | NR | NR | YES: 10% Minority | CHF | NR | 77% (CI 68–84) | Mean: 54 Range: 54–58 | Caucasian: 90% | >$45k/yr: 53% (CI 42–63) | 49% college graduates (CI 39–59) | NR | 100% previous experience using internet, 95% had access to a home computer | 19% (CI 12–27) in Safety Net insurance program for needy patients | NR | English | NR | SPARRO, System Providing Patients Access to Records Online | Secure web access to medical records, guide to heart failure and a messaging system | Group 1: Intervention Group 2: Control | Secure website | Offer patients access to records, lab tests and educational materials | NR | Written user guide | NR | Exercise Endurance Grp 1 vs. Grp 2: 0.74 Pooled: 0.25 Strengthening Grp 1 vs. Grp 2: 0.40 Pooled: 0.95 MOS SF-36 Physical Grp 1 vs. Grp 2: 0.75 Pooled: 1.0 Physical role functioning Grp 1 vs. Grp 2: 0.60 Pooled: 0.14 | NR | NR | NR | Demographic Factors Associate with use of SPARRO Age: p=0.55 Gender (%male): p= 0.63 Race: p= 0.06 Education (%college grad): p= 0.54 HH income >$45000: p= 0.25 Baseline KCCQ symptom (Mean): p= 0.07 Number of clinic visits (Mean): p= 0.10 | NR | Baseline Expectations of Patients and Physicians Patient empowerment: p= 0.01 More questions: p= 0.11 Worry more: p<0.01 reports confusing: p= 0.01 Notes offensive: p= 0.03 Notes confusing: p= 0.35 | General Health Perception Grp 1 vs. Grp 2: 0.71 Pooled: 0.09 | NR | NR | NR | MOS Social Support Offline Grp 1 vs. Grp 2: 0.95 Pooled: 0.25 Online Grp 1 vs. Grp 2: 0.08 Pooled: 0.37 | N = 26 | NR | Limitations include a highly educated patient population, more computer literate and high staff/patient ratio in this clinic
Estabrooks | 2005 | Urban as well as rural | NR Look at Glasgow 2004, Amthauer 2003 has more info on physician and patient recruiting | Doctor's office | Intervention arm of RCT | N = 422 Grp 1 (Reduce fat): 112 Grp 2 (Increase fruits and vegetables): 100 Grp 3 (Increase physical activity): 210 | NR | 6 months | *Age equal to or above 25 yrs *Language: English *Presence of Type 2 Diabetes. | Pts who chose smoking cessation as target behavior were excluded | NR | YES | TYPE 2 DIABETES | NR | Reduce fat: 52.7% Increase fruit and veggies: 49% Increase physical activity: 45% | Mean (SD) Reduce fat: 62 (±13.37) Increase fruits and vegetables: 60 (±11.86) Increase physical activity: 63 (±12.80) | Grp 1 (Reduce fat) Caucasian: 86.5% Hispanic: 10.8% Other: 2.7% Grp 2 (Increase fruits and veggies) Caucasian: 81% Hispanic: 10.9% Other: 8% Grp 3 (Increase physical activity) Caucasia: 83.8% Hispanic: 11% Other: 5.2% | Income Grp 1 (Reduce fat) < $ 10,000: 10.2% $10,000–29,999: 25.9% $30,000–49,999: 33.3% ≥$ 50,000: 30.6% Grp 2 (Increase fruits and veggies) < $ 10,000: 13.5% $10,000–29,999: 30.2% $ 30,000–49,999: 22.9% ≥$ 50,000: 33.3% Grp 3 (Increase physical activity) < $ 10,000: 11.2% $10,000–29,999: 24.9% $ 30,000–49,999: 27.4% ≥$50,000: 36.5% | Grp 1 (Reduce fat) <HS: 12.5% High school graduate: 22.3% College 1–3 yrs: 29.5% College/grad school: 35.7% Grp 2 (Increase fruits and veggies) <HS: 14% High school graduate: 30% College1–3 yrs: 34% College/grad school: 22% Grp 3 (Increase physical activity) <HS: 11% High school grad: 27.1% College1–3 yrs: 33.8% College/grad school: 28.1% | Urban as well as rural | Married % Grp 1: 70.5 Grp 2: 68 Grp 3: 68.1 Median number of co-morbid diseases Grp 1: 2 Grp 2: 2 Grp 3: 2 Diet Fat consumption: Mean (SD), p= 0.28 Grp 1: 22.27 (±7.78) Grp 2: 19.18 (±8.98) Grp 3: 20.49 (±8.48), Fruit and vegetable consumption: Mean (SD), p < 0.0001 Grp 1: 13.5 (±4.94) Grp 2: 10.65 (±3.59) Grp 3: 12.40 (±4.61) Physical activity Days of vigorous activity, p< 0.0001 Grp 1: 0.42 Grp 2: 0.34 Grp 3: 0.29 Days of moderate activity, p< 0.0001 Grp 1: 0.49 Grp 2: 0.45 Grp 3: 0.37 | NR | NR | NR | NR | Diabetes priority program | Clinic based, interactive, self management CD-ROM that allowed pts to select a behavioral goal and receive mail and telephone support for the initial 6 months followed by additional behavioral assessments. | Goal setting component targeted development of tailored action plan based on the pts needs; Pts completed brief assessment of diet and physical activity; Pts selected a behavioral change goal in the area of diet or exercise; interactive session facilitated pts in selecting specific activities to support the goal, identifying barriers and choosing strategies to overcome these barriers; program generated hard copy, minimal coaching involved, Pt then completed brief counseling session with care manager of that practice to provide goal related feedback | Computer (CD-ROM) | Goal setting, Tailored action plan, assessments of dietary intake and physical activity, hard copy of pts personal action plan | NR | NR | NR | Fat consumption, Mean (SD) Baseline vs. 6 months Grp 1: 22.27 (±7.78) vs. 18.42 (±7.99); p < 0.0001 Grp 2: 19.18 (±8.99) vs. 16.84 (±8.75), p=0.0029 Grp 3: 20.49 (±8.49) vs. 19.09 (±7.80), p= 0.0058 Overall comparison= 0.0088 Fruit and veggie consumption, Mean (SD) Baseline vs. 6 months Grp 1: 13.5 (±4.94) vs. 14.12 (±5.07) ; p=0.0967 Grp 2: 10.65 (±3.59) vs. 12.70 (±4.11), p<0.0001 Grp 3: 12.4 (±4.61) vs. 12.86 (±5.20), p= 0.0587 Overall comparison= 0.075 Vigorous activity Baseline vs. 6 months Grp 1: 0.42 vs. 0.46 ; p=0.4594 Grp 2: 0.34 vs. 0.36, p= 0.288 Grp 3: 0.29 vs. 0.37, p= 0.0002 Overall comparison= 0.1634 Moderate activity Baseline to 6 months Grp 1: 0.49 vs. 0.55; p= 0.0917 Grp 2: 0.45 vs. 0.48, p= 0.4515 Grp 3: 0.37 vs. 0.42, p= 0.0156 Overall comparison= 0.6921 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | Grp 1 (N) Baseline vs. 6 months 112 vs. 92 (No reasons given) Grp 2 (N) Baseline vs. 6 months 100 vs. 90 (No reasons given) Grp 3 (N) Baseline vs. 6 months 210 vs. 169 (no reasons given) | NR | No
Ewald | 2006 | 27 clinical practices | 27 clinical practices | Homes/Clinic | Cohort | N=53 | 3 months | None | *Age ≥18 years with essential hypertension requiring antihypertensive therapy | NR | NR | NR | HYPERTENSION | NR | 55% | Mean Age: 57.7 Range: 33–90 | German | NR | NR | NR | Mean (Range) BMI: 28.1 (19–41) Duration of HTN (yrs): 6.4 (0–23) | NR | NR | German | International guidelines for the management of HTN have acknowledged the need to look for alternative methods of BP measurement in order to quantify more precisely the contribution of HTN to CV risk. | TensioPhone 2 telemonitoring BP device | Device stores BP measurement data. Device is an upper-arm oscillometric device with a built-in modem for data teletransmission via standard telephone lines. | All patients used the device for BPSM | BPSM device | To record data, transmit data, and store data | NR | Received instruction on how to operate the BPSM device | HTN medication (lowers BP): olmesartan medoxomil | [underlined: Office Measurements] Systolic (SD)/Diastolic (SD) (mmHG) Baseline (visit 1): 162.6 (±18.7)/96.3 (±13.5) Week 12 (visit 2): 133.5 (±7.7)/79.8 (±5.8) Systolic diff. v. baseline: 29.1 (±16.9) Diastolic diff. v. baseline: 16.5 (±13.2) [underlined: BPSM] Baseline: 147.8 (±16.1)/85.7 (±11.6) Week 9: 138.6 (±13.2)/79.0 (±10.7) Systolic diff. v. baseline: 9.2 (±16.9) Diastolic diff. v. baseline: 6.7 (±8.9) | NR | Assuming none since Germany has a universal health care system | NR | Reduction of BP ≥2 BPSMs/day and 100% compliant: -16.6/-8.0mmHg 1 BPSM/day and 75% compliant: -0.2/-3.3.mmHg | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Ferrer-Roca | 2004b | NR | Island town | Home or Work | Cohort | N = 172 Grp 1 (DM): 12 Grp 2 (Website review only): 160 | September 2002–June 2003 | 9 mos | *Dx of DM *Aged: 18–75 years *Internet access at home or work, or mobile phone with WAP services *Basic knowledge of the IT | NR | NR | YES: rural islanders | DM | NR | NR | Mean (Range): 39 (27–68) | NR | NR | NR | Rural, islanders | NR | NR | NR | NR | NR | Website with patient and doctor interfaces for inputting data and sending advice | Group 1: those who entered the trial to test the system Group 2: those that did not meet study criteria to enter the trial, but reviewed the website only | NR | Website | Education, data input, advice sending | NR | NR | NR | NR | NR | NR | NR | NR | 86% of Grp1 and 40% of Grp 2 would recommend the site (P<0.01) 71 % of Grp1 and 92% of Grp 2 thought the system was easy to use (P<0.05) 33% of Grp 1 and 12% of Grp 2 did not find the system useful and efficient (P<0.05) 50% of Grp 1 and 88% of Grp 2 had difficulties in accessing the system(P<0.01) | Responses were only from Grp1: results are ambiguous, with only 8 subjects completing questions on HIT satisfaction | NR | NR | NR | NR | NR | NR | NR | NR
Ferrer-Roca | 2004a | NR | NR | Homes | Cohort | N= 23 | NR | 8 months | *Pts with diabetes *Access to their own personal mobile phone or access to one belonging to their relative | NR | NR | NR | DIABETES | NR | MR | Range 18–75 0–24 yrs: 19 pts 25–49 yrs: 1 pt 50–75 yrs: 2 pts ≥75: 1 pt | NR | NR | NR | NR | NR | NR | NR | NR | NR | Mobile phone text messaging | Pts used SMS to transmit data (glucose levels and body weight) to a server which automatically answered with an acknowledgement message. A monthly calculated glycosylated hemoglobin result was also automatically sent to the pt by SMS. | Web based server capable of receiving and displaying patient data. Pts entered their blood glucose or other values such as body weight using their mobile phone. The server automatically answered via SMS with a pre recorded acknowledgement when a pt entered a blood glucose value, or with specific help or warning messages when data were wrong or out of range for the individual patient. Each month the system calculated a mean blood glucose value for each pt. Each pt's calculated mean HbA1c value was sent to the pts mobile phone via SMS and stored in the database. Moreover, 4 messages containing advice, automatic reminders or warnings were also sent. | Mobile phone | Data input, SMS, acknowledgement message, monthly glycosylated Hb result through SMS, warnings and reminders | NR | NR | NR | NR | NR | The monthly cost based on pt sending one text message/day for 5 days/wk The std cost of text message was US $ 0.18 The cost / pt was $ 3.6/month A total of 25 messages /month including the monthly report, education, warnings and reminders Cost to the diabetes manager was $4.5. These were compared with hypothetical use of premium SMS calls which cost almost $1.2/message. Thus, cost to the pt would be $24 /month, but the diabetes service would make a profit of $ 8.4/month | NR | Average of 33 SMS server messages / month from the 23 pts. Reduction in reported activity during a holiday period. | Elderly people had difficulty typing the SMS messages and this was instead done by relatives | People criticized the fact that system did not allow data from previous day to be entered. Average scores on pt satisfaction survey Question- SMS users (n=6) Are automatic messages of interest?: 4.2 Are doctors' messages useful?: 3.8 Is your diabetes better controlled with SMS?: 3.0 Do you like the SMS diabetes system?: 4.2 Is your glycosylated Hb level of interest to you?: 4.2 Do you prefer to manage diabetes yourself?: 4.2 Do you prefer doctor to manage your diabetes?: 3.7 What is your level of satisfaction with the SMS system?: 4.3 | NR | NR | NR | NR | NR | NR | NR | NS
Finkelstein | 1996 | Lung transplant recipients | Tertiary care academic center | Home-monitoring | Cohort | N = 41 | 1993-1994 | 12 mos | *Alive and willing | Transplant or training prior to full implementation | NR | NR | LUNG TRANSPLANT | NR | N = 41.46% (17/41) | Mean (SD): 47.1 (±11.7) Range: 15–66 | NR | NR | NR | NR | NR | NR | NR | NR | NR | Electronic spirometer/diary | Daily home monitoring of symptoms and vital signs in electronic diary, plus automatic recording of spirometer data, with weekly transmission to clinic | All patients received home monitoring diary instrument, plus initial training, weekly phone calls, quarterly newsletter, a hotline, plus usual care | Home spirometer with electronic diary and automatic weekly modem transmission of data | Tracking symptoms and signs | NR | Initial training, weekly phone calls, quarterly newsletter, a hotline, | Weekly phone calls, quarterly newsletter, a hotline | NR | NR | Estimate 4.5–5 minutes per patient per week staff time, over usual care | NR | 8941 transmissions by 41 subjects in 52 weeks; initial 6.2/wk, stable over 3.9/wk; 98% complete symptoms, vital signs, 100% complete spirometry | NR | NR | NR | NR | NR | NR | NR | None (121 screened; 4 refused; 6 unstable; 33 deaths, 37 before intervention ready = 41) | NR | NR
Franklin | 2006 | NR | Pediatric Clinics, Tayside | Homes | RCT | N = 92 Grp 1: 28 Grp 2: 33 Grp 3: 31 | October 2002–February 2003 | NR | *Type I Diabetes for > 1 year *Tx with insulin therapy (2 or 3 injections per day) | Serious social problems, severe learning disabilities, needle phobia | NR | NR | TYPE 1 DIABETES | NR | Grp 1: 63% Grp 2: 45% Grp 3: 55% | Mean Grp 1: 12.7 Grp 2: 14.1 Grp 3: 12.6 | Not Caucasian Grp 1: 4 pts Grp 2: 3 pts Grp 3: 3 pts | NR | NR | NR | NR | NR | NR | NR | NR | Sweet Talk | Automated mobile phone text-messaging support system, goal setting | Group 1: Conventional insulin therapy (CIT) Group 2: CIT plus Sweet Talk Group 3: Basal bolus or pump therapy, Sweet Talk, nutrition counseling All patients received 3–4 month clinic visits and access to emergency hotline | Phone | Text messages, reminders | Goal setting training for diabetes team by team psychologist; details NR | NR | NR | HbA1c: Group 1 vs. Group 2: 10.1±1.7, 95% CI -0.7, +0.7, P= 0.99 Group 2 vs. Group 3: : 9.2±2.2, 95% CI -1.9, -0.5, P <0.001 Diabetic ketoacidosis (DKA); episodes Group 1 vs. Group 2: 3 vs. 2, P= 0.58 Group 2 vs. Group 3: 2 vs. 7, P=0.10 Severe hypoglycemia; episodes Group 1 vs. Group 2: 4 vs. 1, P= 0.63 Group 2 vs. Group 3: 1 vs. 2, P= 0.37 | NR | NR | NR | NR | NR | NR | NR | Self-efficacy for diabetes (SED) score: Group 1 vs. Group 2 56.0+ 13.7 vs. 62.1+6.6, 95% CI +2.6, + 7.5, P=0.003 Group 2 vs. Group 3 62.1+6.6 vs. 63.1+ 7.2, 95% CI -2.1,+4.2, P=0.50 | Adherence score (Visual analog scale- self-report) Group 1 vs. Group 2: 70.4 (±20.0) vs. 77.2 (±16.1), 95% CI +0.4, +17.4, P=0.042 Group 2 vs. Group 3: 77.2 (±16.1) vs. 78.8 (±16.2), 95% CI -7.0, +8.0, P=0.90 | NR | Diabetes social support interview (DSSI): Family and friends: Group 1 vs. Group 2: NS, data not provided Group 2 vs. Group 3: NS, data not provided | NR | NR | Diabetes social support received from diabetes team Group 1 vs. Group 2: Group 2 vs. Group 3:
Frenn | 2005 | Urban public middle school | NA | Computer lab | Nonrandomized between group | N= 137 IG: 43 CG: 60 | NR | 1 month | NR | NR | NR | YES | NR | NR | IG Diet More than 3 sessions: 30% Less than 3 sessions of diet: 33.3% Activity More than 2 sessions: 26.3% Less than 2 sessions: 33.3% CG Diet: 44.9% Activity: 50% | 12 yrs IG Diet More than 3 sessions: 45% Less than 3 sessions of diet: 50% Activity More than 2 sessions: 51.2%% Less than 2 sessions: 25% CG Diet: 51% Activity: 46.7% 13 yrs IG Diet More than 3 sessions: 42.5% Less than 3 sessions of diet: 16.7% Activity More than 2 sessions: 37.2% Less than 2 sessions: 50% CG Diet: 34.7% Activity: 41.7% 14 yrs IG Diet More than 3 sessions: 12.5% Less than 3 sessions of diet: 33.3% Activity More than 2 sessions: 11.6% Less than 2 sessions: 25% CG Diet: 14.3% Activity: 11.7% | Asian IG Diet More than 3 sessions: 0% Less than 3 sessions of diet: 0% Activity More than 2 sessions: 0% Less than 2 sessions: 0% CG Diet: 4.1% Activity: 5% Black IG Diet More than 3 sessions: 20% Less than 3 sessions of diet: 50% Activity More than 2 sessions: 20.9% Less than 2 sessions: 33.3% CG Diet: 30.6% Activity: 26.7% Hispanic IG Diet More than 3 sessions: 55% Less than 3 sessions of diet: 16.7% Activity More than 2 sessions: 53.3% Less than 2 sessions: 41.7% CG Diet: 34.7% Activity: 40.0% Native American IG Diet More than 3 sessions: 2.5% Less than 3 sessions of diet: 0% Activity More than 2 sessions: 0% Less than 2 sessions: 8.3% CG Diet: 8.2% Activity: 6.5% White IG Diet More than 3 sessions: 12.5% Less than 3 sessions of diet: 0% Activity More than 2 sessions: 9.3% Less than 2 sessions: 8.3% CG Diet: 8.2% Activity: 8.9% Other IG Diet More than 3 sessions: 10% Less than 3 sessions of diet: 33.3% Activity More than 2 sessions: 16.3% Less than 2 sessions: 8.3% CG Diet: 14.3% Activity: 15% | Free lunch IG Diet More than 3 sessions: 75% Less than 3 sessions of diet: 66.7% Activity More than 2 sessions: 72.1% Less than 2 sessions: 75% CG Diet: 71.4% Activity: 70% Reduced IG Diet More than 3 sessions: 12.5% Less than 3 sessions of diet: 0% Activity More than 2 sessions: 14% Less than 2 sessions: 8.3% CG Diet: 12.2% Activity: 13.3% No reduction IG Diet More than 3 sessions: 12.5% Less than 3 sessions of diet: 33.3% Activity More than 2 sessions: 14% Less than 2 sessions: 16.7% CG Diet: 16% Activity: 16.7% | NR | Urban public middle school | NR | NR | NR | NR | NR | Internet/video exercise and low fat diet intervention | Eight session health promotion/transtheoretical model internet/video delivered intervention to increase physical activity and reduce dietary fat among low income, culturally diverse, seventh grade students. | IG: Eight session blackboard platform delivered internet approach with 4 two to three min videos. Focus of the intervention on strategies appropriate for all stages of change, particularly for those in precontemplation and contemplation stages. (concepts included consciousness raising, self reevaluation, improve access to healthy foods and physical activity, decisional balance including reduce barriers to healthy foods and physical activity and emphasize benefits for healthy foods and physical activity). Computer generated tailored feedback provided for physical activity and dietary fat; 10 discussion board answers for which individualized e mailed feedback provided; structured workbook provided to record notes. CG: Comprised of three seventh grade science classes who had their usual assignments | Computer | Education, tailored feedback, emails, discussion board | NR | NR | NR | Exercise: IG students who completed more than half the sessions increased moderate/vigorous exercise by an average of 22 mins compared with a decrease of 46 mins for the control group t (103)= - 1.99, p=0.05 Those who completed all 3 sessions (n=39) increased activity by 33 mins. Dietary fat: IG students participating in more than half of the sessions decreased dietary fat from 30.7 % to 29.9%, t(87)= 2.73, p=0.008 CG students had 31.5% dietary fat pretest and 31.6% dietary fat post test. | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | IG students who did not complete half the exercises and not included in the analysis=12 IG students who participated in less than half the sessions (dietary fat) and removed from analysis = 6 | NR | Change in activity of IG students who did not complete half the exercises not significantly different from the control students, t (13)= 1.53, p=0.15 IG students participating in less than half the sessions on dietary fat were not significantly different than students in the control group, t (16.6)= -1.843, p=0.08 Pre and post test activity and dietary fat for subjects in each stage of change shown in graphic form Graphs depicting comparative subgroup changes in dietary fat and exercise given but very difficult to obtain precise values Subgroup analysis Activity; For IG students participating in more than half the activity sessions, moderate and vigorous activity were increased for all racial group For CG students, activity decreased in each racial grp Dietary fat; For IG students participating in more than half the sessions, decreased for all racial groups For CG students, increased for African Americans and Hispanics and decreased less for whites.
Gega | 2004 | NR | Computer aided self-help clinic | Fearfighter: mostly in clinic, occasionally at a free internet café or a medical center, some could access it at home or elsewhere linked to the internet after it became available on the web Cope and BTSteps: self help booklets given and free phone calls made by pts from home to the IVR system. Balance: accessed system by PC with a CD-ROM drive at the clinic, home, free internet cafe or a physician's office. | Case Study; Cohort | N= 210 | 12 months | Fearfighter, cope and BT steps=12 weeks Balance=4 weeks | Presence of an anxiety and depressive disorder, motivation to do self help, and no substance abuse, psychosis or active suicidal plans | NR | NR | NR | ANXIETY or DEPRESSIVE DISORDER | NR | Slightly under half were men (no raw data available) | NR | NR | NR | A third were unemployed or students (no raw data) | NR | Mean problem duration: 8 yrs with moderately severe problems 39% had given up work/long term sick leave Almost 1/2 were having current treatment from their physician or a mental health professional 1/2 were on psychotropic medication (no raw data) 20% had CBT previously 35% used computers most days at work Broad diagnosis Depression: 71 Phobia/panic disorder: 60 Generalized anxiety disorder: 35 Obsessive compulsive disorder: 35 Stress/adjustment disorder: 26 mixed Anxiety/depression: 7 Somatoform disorder: 6 | NR | NR | NR | NR | Computer aided systems of cognitive behavior therapy (CCBT) (Fearfighter, Cope, Balance and BTSteps) | Systems of cognitive behavior therapy accessible at home included fearfighter for phobia/panic; Cope for non-suicidal depression; BTSteps for Obsessive compulsive disorder; Balance for generalized anxiety/mild depression. | CCBT systems help the pts make most of the decisions about how to devise, execute and complete CBT including appropriate homework and relapse prevention. The therapist's role was restricted to briefly screening the patient and offering live advice (by phone) if pt got stuck during CCBT. The clinic's pt accessed Cope and BT Steps by phoning a computer on an interactive voice response system (IVR) system after reading a manual. Computer faxed to the clinic weekly reports of phone calls, duration, modules accessed and for Cope pts, suicide risk Balance and Fearfighter could be accessed via internet and Balance had a CD-ROM form too Pts told to use the system as much as possible; pts advised to use fearfighter cope or BTSteps at 6 times over 12 weeks, they also had brief scheduled therapist contacts by phone or fact to face for advice. Pts using Balance asked to use it 3 times over 4 weeks and have 3 brief therapist contacts by phone/face to face | Computer, phone | Cognitive behavior therapy, IVR | NR | Pts were given manuals to read before calling the Cope and BTSteps system | NR | NR | NR | Assuming administrative costs and 15% overheads, the estimated per pt cost advantage of CCBT over face to face CBT would rise from 15% /pt for 350 pts a yr to 41% per pt for 1,350 pts a yr The total cost of CCBT nationally might rise if many users who were previously untreated sought CCBT to offset savings from lower per patient cost | NR | Mean of 58 days from pts starting CCBT to ending it. In this period, mean of 64 mins support from the clinician The clinic' pts who accessed computer by phone spent similar total times calling the computer as in previous studies- 2 hrs on Cope calls and 4 hrs on BT Steps calls. | NR | Pts fairly satisfied with their CCBT system and satisfied even more with live support and self help clinic as a whole. Marginal preference for therapist over computer guidance seen satisfaction and preference ratings were similar among users of he four different systems. | NR | Significant improvement on work/social adjustment for fearfighter, cope and balance users. Significant improvement from pre to post treatment on measures specific to their problem for completers of each self help Clinically meaningful effect size of 0.8 or more exceeded by fearfighter users on the FQ's global phobia and anxiety/depression scores; by cope users on depression and on work/social adjustment; and by BTSteps users on obsessive compulsive total and sub scores. Completers improved comparably to completers in other studies that used the CCBT system and measures. | NR | NR | NR | Over 12 months intake, screening questionnaires received=355 unsuitable on the questionnaire= 8% screening interview with a clinician offered to= 327 attended=266 suitable=210 refused CCBT= 42 (20%) dropped out early or gave no post treatment data= 60 (29%) | NR | 3 case illustrations discussed.
Gerber | 2007 | Inner city | Inner city clinics and Childhood diabetes registry | Homes | Cohort | N=19 | NR | 6 months | NR | NR | NR | YES: inner city | DIABETES: Types 1 and 2 | NR | Total: 32% | Mean age: 22.3 yrs (19–26) | African-American: 84% | NR | Finished high school: 74% | Urban | Had received diabetes education previously: 74% Had diabetes related complication: 37% Out of 13 women, 7 had ay least one child Computer at home: 21% Current use of computer at work or school: 47% Very comfortable with computer: 84% Somewhat comfortable: 3% | Public aid: 53% No health insurance: 21% Unemployed or disabled: 37% | NR | NR | NR | STYLE- Self management training in youth for lifelong effectiveness | Internet based transition support program consisting of background information on diabetes, goal setting exercises with individualized feedback, role playing, group discussions, empowerment activities and communication skills training designed to improve interactions with health professionals. | Internet based program on commercial course management software. Each week, a diabetes educator introduced a new module with an activity and feedback evaluation form and monitored the discussion board. This board provided encouragement, discussion of clinical and logistic problems and prevented sharing of misinformation. Three “ask an expert” segments allowed pts to consult with psychologist, patient advocacy expert and a social worker with experience in diabetes related health care access. | Computer | Information on diabetes, goal setting exercises with individualized feedback, role playing, group discussions, | NR | NR | NR | 83% stated that they experienced greater control of their diabetes following completion of modules | NR | NR | NR | STYLE accessed a total of 4445 times 25.8% of all hits were between 9 PM– 11 PM STYLE used maximum in the first 2 months (1460 and 1417 hits respectively) Use declined 262 times the 6th month. Discussion board had the heaviest use (4–576 per participant, median 57, SD=148.5) 50% completed modules within 30 mins, additional 30% spent 30–60 mins on the modules | 50% felt that the modules were very easy or easy to complete with the remainder describing them as somewhat hard. 67% reported trouble completing module activities on time often due to work, school and family commitments | Overall, every one of the pts indicated that the module was very helpful. | NR | NR | NR | NR | 50% received encouragement from family members often or very often to log in to STYLE. | NR | NR | Qualitative results on the discussion board reported, not listed here
Gerbert | 2003 | 3 primary care clinics | San Francisco Bay Area, CA | Clinic | RCT | N=52 | NR | NR | *Ages 18–65 *Smokes tobacco and/or drinks alcohol | Outside age range, does not smoke tobacco or drink | NR | YES: recruited from clinic that primarily serves low-income individuals on Medi-Cal | YES: SMOKING and/or DRINKING ALCOHOL | NR | 48.00% | Range: 18–65 | African-American: 48% Caucasian: 23% Latino: 12% Asian: 10% Other: 8% | NR | NR | NR | Current Smokers: 31% Drinking at risky or hazardous levels: 40% Combination: 29% | NR | NR | NR | NR | Project Choice | This “video doctor” is an interactive, multimedia video doctor, that helps reduce primary care pts smoking and alcohol use by: a) a patient-centered advice message and b) a brief motivational intervention tailored to the information input by the pt | CG: 16 Video doctor-advice message: 18 Video doctor-advice message + brief intervention: 18 | Interactive multimedia software | To provide suggestions about how to quit smoking/drinking to pts | NR | NR | NR | NR | NR | NR | NR | NR | 7 point scale Mean: 6.79 | 7 point scale Mean: 5.69 | NR | NR | 7 point scale intention to change behavior Smokers: 5.94 Alcohol Users: 4.42 | NR | NR | NR | NR | NR
Glasgow | 2000 | Outpatients | Primary care physicians- small group practices | Center for healthy living, centralized location for most pts | RCT | N= 320 Grp 1 (no Telephone [TF], no Community resources[CR]): 80 Grp 2 (no TF, CR): 80 Grp 3 (TF, no CR): 80 Grp 4 (TF, CR): 80 | NR | 6 months | *Meeting the Welborn criteria for Type 2 diabetes on the basis of age at diagnosis, body mass index, and when insulin was begun *Age >40 yrs *Living independently *Have a telephone *Not planning to move out of the area during the next year | NR | NR | NR | DIABETES | NR | TF, CR: 43.6% TF, no CR: 43% No TF, CR: 52.6% No TF, no CR: 33.7% | Mean (SD): (TF, CR) vs. (TF, no CR) vs. (No TF, CR) vs. (No TF, CR) 57.4 (± 9.4) vs. 59 (±9.6) vs. 60.5 (±8.6) vs. 60.6 (±9.5) | Caucasian TF, CR: 91.4% TF, no CR: 88.6% No TF, CR: 90.9% No TF, CR: 90.0% | NR | Some college or more TF, CR: 58.0% TF, no CR: 63.0% No TF, CR: 59.7% No TF, CR: 46.3% | Unclear | Retired, % (TF, CR) vs. (TF, no CR) vs. (No TF, CR) vs. (No TF, CR) 35.8 vs. 31.6 vs. 28.6 vs. 45.0 Live alone, % (TF, CR) vs. (TF, no CR) vs. (No TF, CR) vs. (No TF, CR) 64.2 vs. 44.3 vs. 58.4 vs. 51.2 Years diagnosed, mean(SD) (TF, CR) vs. (TF, no CR) vs. (No TF, CR) vs. (No TF, CR) 6.4 (5.9) vs. 7 (6.7) vs. 6.8 (7.6) vs. 5.1 (4.3) On insulin, % (TF, CR) vs. (TF, no CR) vs. (No TF, CR) vs. (No TF, CR) 14.8 vs. 16.5 vs. 15.8 vs. 15.0 Previous diabetes education, % (TF, CR) vs. (TF, no CR) vs. (No TF, CR) vs. (No TF, CR) 58 vs. 62 vs. 51.9 vs. 47.5 equal to or more than 1 chronic illness, % (TF, CR) vs. (TF, no CR) vs. (No TF, CR) vs. (No TF, CR) 85.2 vs. 79.0 vs. 79.2 vs. 85.0 | NR | NR | NR | NR | Choosing Well project | Interactive multimedia touch screen, computer assessment and feedback session The computer interaction assessed, immediately analyzed and provide feedback on the patient's dietary patterns, barriers to and support for dietary self management and preferences for different intervention strategies. The session concluded with a tailored dietary fat reduction goal based on the participant's eating patterns and preferences and a 1 page goals printout summarizing this info. Telephone FU- consisted of brief, structured calls to provide ongoing support and reinforcements to pts via continued contact with interventionist who met pts during the office visit. also provided personalized problem solving training based on barriers to dietary self care identified via touch screen assessment. Pts received 3–4 FU calls before the 6th month FU Community resources- a 3 ring binder of indexed community resources, a total of 4 newsletters identifying opportunities to obtain support for eating patterns, and goal setting for community nutrition support activities. Pts returned postcard stating which CR they had used. Food frequency questionnaire mailed and personally tailored feedback provided to decrease fat intake. | Grp 1: no Telephone (TF), no Community resources(CR) Basic intervention pts received the above and a general pamphlet on low fat eating Grp 2: No Telephone Follow up but community resources provided Grp 3: Telephone follow up, no community resources Grp 4: Telephone FU and community resources provided | Computer | Assessment, education, analysis and tailored feedback | NR | NR | NR | HBA1c, p=NS, n=267 (No TF, no CR) vs. (no TF, CR) vs. (TF, no CR) vs. (TF, CR) Baseline- 7.6(1.2) vs. 7.3 (1.5) vs. 7.5 (1.9) vs. 7.6 (1.8) 3 month FU- 7.6 (1.4) vs. 7.3 (1.6) vs. 7.6 (2.1) vs. 7.5 (1.7) 6 month FU- 7.4 (1.2) vs. 7.3 (1.4) vs. 7.4 (1.4) vs. 7.5 (1.7) Total Cholesterol, p=0.010, n=266 (No TF, no CR) vs. (no TF, CR) vs. (TF, no CR) vs. (TF, CR) Baseline-210 (40) vs. 203 (39) vs. 202 (38) vs. 205 (35) 3 month FU-201(34) vs. 202 (34) vs. 198(37) vs. 201 (31) 6 month FU- 206(39) vs. 194(30) vs. 202(39) vs. 201 (30) Weight, NS, n=265 (No TF, no CR) vs. (no TF, CR) vs. (TF, no CR) vs. (TF, CR) Baseline- 199(36) vs. 212(49) vs. 219949) vs. 221(52) 3 month FU- 198(37) vs. 210(46) vs. 217(47) vs. 218(49) 6 month FU- 197(37) vs. 210(46) vs. 217(48) vs. 219 (51) Lipid ratio: total/HDL, NS, n=266 (No TF, no CR) vs. (no TF, CR) vs. (TF, no CR) vs. (TF, CR) Baseline-5.1(1.7) vs. 5.1(2.7) vs. 5.2(3.8) vs. 4.9(1.4) 3 month FU-4.9(1.5) vs. 4.9(1.4) vs. 4.6(1.3) vs. 4.9(1.7) 6 month FU- 4.9(2.2) vs. 4.6(1.3) vs. 4.5(1.1) vs. 4.7(1.2) | NR | NR | NR | NR | NR | Satisfaction with the program 3 month Follow Up, p=NS, n=290 No TF, no CR: 36 (±5.5) No TF, CR: 35 (+5.5) TF, no CR: 36 (±4.7) TF, CR: 37 (±4.3) | NR | NR | Block fat screener, p-NS, n=265 (No TF, no CR) vs. (no TF, CR) vs. (TF, no CR) vs. (TF, CR) Baseline: 48.6 (±28.5) vs. 49.0 (±27.2) vs. 48.8 (±30.6) vs. 54.5 (±33.8) 3 month FU: 26.2 (±17.1) vs. 23.8 (±15.2) vs. 26.8 (±19.0) vs. 26.9 (±23.2) 6 month FU: 24.7 (±17.5) vs. 23.9 (±14.4) vs. 25.7 (±19.2) vs. 22.8 (±17.4) Kristal FFB fat composite, p=0.017, n=265 (No TF, no CR) vs. (no TF, CR) vs. (TF, no CR) vs. (TF, CR) Baseline: 1.9 (±0.5) vs. 1.9 (±0.5) vs. 2.0 (±0.4) vs. 1.9 (±0.5) 3 month FU: 1.9 (±0.5) vs. 1.9 (±0.5) vs. 1.9 (±0.4) vs. 1.8 (±0.5) 6 month FU: 1.6 (±0.4) vs. 1.8 (±0.4) vs. 1.7 (±0.4) vs. 1.6 (±0.4) Kristal FFB fruit and vegetable scale, p= 0.045, n=265 (No TF, no CR) vs. (no TF, CR) vs. (TF, no CR) vs. (TF, CR) Baseline: 1.9 (±0.8) vs. 2.0 (±0.8) vs. 2.2 (±0.8) vs. 2.0 (±0.8) 3 month FU: 1.8 (±0.8) vs. 1.9 (±0.8) vs. 2.1 (±0.8) vs. 1.9 (±0.9) 6 month FU: 1.7 (±0.8) vs. 2.0 (±0.8) vs. 1.9 (±0.8) vs. 1.9 (±0.8) | Diabetes intrusiveness, p= 0.014, n=267 (No TF, no CR) vs. (no TF, CR) vs. (TF, no CR) vs. (TF, CR) Baseline: 25.7(11.1) vs. 29.2 (15.2) vs. 28.6 (12.0) vs. 30.8(15.7) 3 month FU: 31.0 (15.6) vs. 30.6(15.0) vs. 32.4(13.0) vs. 31.4(13.3) 6 month FU: 26.0(12.7) vs. 29.6(14.9) vs. 28.2(12.40 vs. 29.2(14.0) | NR | Attempt to contact: 706 pts Ineligible: 164 (Type 1 DM, not in the area, no telephone) Never reached: 72 (incorrect phone numbers) Asked not to be contacted: 51 Declined participation: 99 (not interested in dietary change, not perceiving a problem, too ill, project time too consuming) Participants: 320 At the 6 month FU, 43 failed to provide data 5–13 per condition ANOVAs failed to reveal any main effect or interactions involving dropout status further attrition analysis not performed | NR | A series of ANOVAs conducted to determine whether there are any differences in demographic or dietary history/severity variables between pts. Table on intervention implementation by condition given, not listed here
Glasgow | 2003 | NR | Primary care medial office | Homes | RCT | N= 320 | NR | 10 months | *Pts taking insulin met the Welborn criteria based on age at diagnosis, BMI and age of insulin initiation *Pts were living independently *Have a telephone *Read and write English *Diagnosed with Type 2 diabetes for at least 1 year *Not planning to move out of the area during the next year | NR | NR | NR | TYPE 2 DIABETES MELLITUS | NR | N = 150 pts (47%) | Mean (SD): 59 (±9.2) | NR | NR | NR | NR | NR | NR | NR | NR | NR | Diabetes network (D- Net) | Internet based self management project evaluating the incremental effects of adding tailored self management (TSM) training or peer support components to a basic internet based, information focused comparison The TSM intervention addressed self efficacy through internet-mediated modeling, accomplishment of graduated goals and development of individual and situation specific problem solving strategies. Pts had access to professional “coach” (could access twice per week) and resources to reach their dietary goals tailored to their needs. Pts also had access to online “dietitian question and answer” conference covering specific topics. They could enter and receive graphical feedback on their pattern of blood glucose levels for different periods of the day. Coaches focused on increasing fruit and veggie consumption in latter part and pts had access to a personal database to enter info about heir daily intake Social support theory was the framework for peer support intervention. Pts participated in activities that allowed to exchange diabetes related info, coping strategies and emotional support. Diabetes support conference was a peer directed forum for pts to interact with one another. A structured support conference called focus forum was more topic oriented. Pts also had live chat discussions, received electronic newsletters with info on community resources and real life success stories and more. | Information only group: Pts had access to extensive number of articles on topics of medical, nutritional, and lifestyle aspects of diabetes. These provided info only and not individually tailored recommendations. Pts completed assessments online and received automated dietary change goals based on their current levels. TSM Grp: same as above Peer support Grp: same as above | Computer | Live chat, logs, databases, information, forums | NR | Pts received in home training in use of computer of approximately two to three visits of 1–2 hrs each | NR | Dietary outcomes Kristal total No peer support (No PS) vs. Peer support (PS) Baseline mean(SD) 2.22 (0.41) vs. 2.19(0.50) 10 month adjusted mean(SD) 2.00(0.38) vs. 1.96(0.38) Group differences- 0.04, MANCOVA/univariate p level- 0.399 No TSM vs. TSM Baseline mean(SD) 2.22(0.45) vs. 2.19(0.46) 10 month adjusted mean 2.03 (0.38) vs. 1.93(0.38) grp differences- 0.10, MANCOVA/univariate p level- 0.048 Estimated gms of daily fat No PS vs. PS Baseline mean(SD) 41.3(26.4)vs. 44.0(31.9) 10 month adjusted mean(SD) 29.8(14.3) vs. 27.9(14.3) Group differences-1.85, MANCOVA/univariate p level-0.323 No TSM vs. TSM Baseline mean(SD) 44.4(33.8) vs. 40.8(23.8) 10 month adjusted mean 29.8(14.3)vs. 27.9(14.3) grp differences-1.98, MANCOVA/univariate p level- 0.292 Physical activity and guidelines Avg minutes activity per day No PS vs. PS Baseline mean(SD) 30.7(24.1) vs29.4(22.3) 10 month adjusted mean(SD) 32.5(22.8)vs. 30.5(22.8) Group differences- 1.96, MANCOVA/univariate p level-0.512 No TSM vs. TSM Baseline mean(SD) 26.8 (20.4)vs. 33.4(25.4) 10 month adjusted mean 32.1(22.9) vs. 30.9 (23.0) grp differences-1.25, MANCOVA/univariate p level-0.680 A1c hemoglobin (%) No PS vs. PS Baseline mean(SD) 7.35(1.56) vs7.54(1.68) 10 month adjusted mean(SD) 7.68(1.10) vs. 7.42(1.10) Group differences-0.28, MANCOVA/univariate p level-0.051 No TSM vs. TSM Baseline Mean (SD) 7.43 (±1.71) vs. 7.45 (+1.53) 10 month adjusted mean 7.67 (±1.10) vs. 7.42 (±1.10) Grp differences: 0.26- MANCOVA/univariate p level-0.074 Lipid ratio No PS vs. PS Baseline Mean (SD) 5.44 (±1.79) vs. 5.43 (±1.59) 10 month adjusted Mean(SD) 5.13 (±1.16) vs. 5.02 (±1.16) Group differences: -0.11 MANCOVA/univariate p level-0.478 No TSM vs. TSM Baseline Mean (SD) 5.18 (±1.44) vs. 5.70 (±1.89) 10 month adjusted mean 5.02 (±1.17) vs. 5.13 (±1.16) Grp differences: -0.10 MANCOVA/univariate p level-0.496 | NR | NR | NR | Average logons per participant per month PS vs. No PS Month 1–3: 18.7 vs. 9.4 Month 4–6: 13.2 vs. 5.1 Months 7–10: 6.7 vs. 3.6 TSM vs. No TSM Months 1–3: 16.7 vs. 11.4 Months 4–6: 9.8 vs. 8.5 Months 7–10: 5.3 vs. 5.0 | NR | NR | NR | Psychosocial outcomes CES-D Total No PS vs. PS Baseline mean(SD) 17.8(10.08) vs. 18.1(10.51) 10 month adjusted mean(SD) 14.06(9.12) vs. 12.59(9.13) Group differences-1.47, MANCOVA/univariate p level-0.219 No TSM vs. TSM Baseline mean(SD) 17.9(10.56)vs. 18.0(10.02) 10 month adjusted mean 12.93(9.11) vs. 3.72(9.12) grp differences= -0.79, MANCOVA/univariate p level-0.507 | NR | NR | No PS vs. PS Baseline Mean (SD) 4.23 (±1.23) vs. 4.05 (±1.28) 10 month adjusted Mean (SD) 4.71 (±1.12) vs. 5.22 (±1.11) Group differences= -0.51, MANCOVA/univariate p level-0.001 No TSM vs. TSM Baseline Mean (SD) 4.14 (±1.32) vs. 4.14 (±1.20) 10 month adjusted mean 4.96 (±1.12) vs. 4.97 (±1.12) Grp differences= -0.01, MANCOVA/univariate p level-0.934 | Data were collected on 82% of the randomized participants Analyses of those present and those not present done and did not show significant effects | NR | Overall change from baseline to10 month follow-up given but not listed here
Gomez | 2002a | NR | Immune Dev. Trust-London, The Lambeth, Southwark and Lewisham Health Authority - London and Apoyo Positivo - Madrid. | NR | NR | NR | NR | NR | *Patient has HIV/AIDS | NR | NR | NR | HIV/AIDS | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | English, Spanish | NR | SEAHORSE II | Web based self monitoring system for HIV/AIDS patient care | NR | Web interface | Self-monitoring personal diary, remote doctor support, data analysis, allows user to post comments and articles | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Green | 2008 | 10 Medical Centers within Group Health | Washington and Idaho | Homes | RCT | N=778 | June 2005–December 2007 | 12 mos | *Ages 25–75 *HTN diagnosis and taking HTN medications *Ability to use a computer *Internet access *E-mail address *Willingness to attend screening sessions at a clinic *Diastolic BP 90–109 mmHg *Systolic BP 140–190 mmHg *Written informed consent | Posessing diseases other than HTN such as diabetes, cardiovascular or renal disease, unable to use a computer, lack of access to the internet, no e-mail address, unwilling to attend screening sesions | NR | NR | HTN | NR | Overall: 47.8% UC: 55.3% IVR: 54.1% IVR + pharmacist care: 44.1% | Overall: 59.1 (±8.5) UC: 56.8 (±8.5) IVR: 59.5 (±8.3) IVR + PC: 59.3 (±8.6) | Overall (%) Caucasian: 82.8 African-American: 7.8 Asian: 3.7 Other: 5.7 UC Caucasian: 82.9 African-American: 8.5 Asian: 3.1 Other: 5.4 IVR + PC Caucasian: 86.1 African-American: 6.9 Asian: 3.5 Other: 3.5 IVR + PC Caucasian: 79.3 African-American: 8.0 Asian: 4.6 Other: 8.0 | NR | Overall (%) <12 yrs or GED: 8.0 Some Post-HS: 41.6 4 yr College Degree: 25.1 Graduate School: 25.3 UC <12 yrs or GED: 8.5 Some Post-HS: 45.3 4 yr College Degree: 18.6 Graduate School: 27.5 IVR <12 yrs or GED: 7.3 Some Post-HS: 42.5 4 yr College Degree: 27.8 Graduate School: 22.4 IVR + PC <12 yrs or GED: 8.0 Some Post-HS: 37.2 4 yr College Degree: 28.7 Graduate School: 26.1 | NR | Antihypertensive Medication Classes Overall (%) 0: 3.6 1: 47.0 2: 33.5 >3: 15.8 UC (%) 0: 5.0 1: 49.2 2: 34.5 >3: 11.2 IVR (%) 0: 1.9 1: 46.3 2: 33.2 >3: 18.5 IVR + PC (%) 0: 3.8 1: 45.6 2: 33.0 >3: 17.6 BP, Mean (SD) mmHg Overall Systolic: 151.9 (±10.3) Diastolic: 89.1 (±8.0) UC Systolic: 151.3 (±10.6) Diastolic: 89.4 (±8.0) IVR Systolic: 152.2 (±10.0) Diastolic: 89.0 (±7.9) IVR + PC Systolic: 152.2 (±10.4) Diastolic: 88.9 (±8.1) | NR | NR | English | NR | NR | Access to Group Health's secure patient Web services (e-mail access, refilling prescriptions, health library, links to behavioral and lifestyle changes, etc), Group Health's HTN pamphlet, home blood pressure monitoring cuff | UC (n=258): Usual HTN care from physicians IVR (n=259): access to Group Health's web services and home blood pressure monitoring system IVR + PC (n=261): acces to Group Health's web services and home blood pressure monitoring system and phamacist intervention to help lower BP | Webserver and home BP monitoring cuff | Education, data input, data collection, tailored feedback | NR | Subject training on home blood pressure monitoring kit | Pharmacist assisted intervention | Subanalysis of Pts with Systolic BP at Baseline > 160 mmHg (n=150) Systolic BP (95% CI) Unadjusted mean UC (N=51): 152.4 (148.2 to 156.6) IVR (N=47): 151.0 (146.6 to 155.2) IVR + PC (N=52): 139.8 (135.6 to 144.0) Overall P Value: < 0.001 UC: 0.64 UC vs IVR + PC: <0.001 IVR vs IVR + PC: <0.001 Adjusted mean change UC: -14.4 (-18.6 to -10.1) IVR: -17.8 (-22.2 to -13.4) IVR + PC: -27.6 (-31.8 to -23.4) Overall P Value: < 0.001 UC: 0.30 UC vs IVR + PC: <0.001 IVR vs IVR + PC: 0.002 Diastolic BP (95% CI) Unadjusted mean UC: 84.4 (81.6 6o 87.2) IVR: 83.8 (80.9 to 86.7) IVR + PC: 81.0 (78.2 to 83.3) Overall P Value: 0.21 UC: 0.78 UC vs IVR + PC: 0.10 IVR vs IVR + PC: 0.10 Adjusted mean change UC: -5.6 (-8.0 to -3.2) IVR: -6.3 (-8.8 to -3.8) IVR + PC: -10.2 (-12.6 to -7.8) Overall P Value: 0.02 UC: 0.70 UC vs IVR + PC: 0.01 IVR vs IVR + PC: 0.03 BP controlled (95% CI) unadjusted proportion UC: 0.20 (0.11 to 0.33) IVR: 0.26 (0.15 to 0.40) IVR + PC: 0.54 (0.40 to 0.67) Overall P Value: <0.001 UC: 0.20 UC vs IVR + PC: <0.001 IVR vs IVR + PC: <0.001 Adjusted RR UC: 1 IVR: 1.88 (0.94 to 3.78) IVR + PC: 3.32 (1.86 to 5.94) Overall P Value: <0.001 UC: 0.08 UC vs IVR + PC: <0.001 IVR vs IVR + PC: 0.05 Outcomes for Patients Completing 12-mo Follow-Up Systolic BP (95% CI) Unadjusted mean UC (N=247): 146.3 (144.5 to 148.2) IVR (N=246): 143.8 (141.9 to 145.6) IVR + PC (N=237): 137.9 (136.0 to 139.8) Overall P Value: < 0.001 UC: 0.06 UC vs IVR + PC: <0.001 IVR vs IVR + PC: <0.001 Adjusted mean change UC: -5.3 (-7.1 to -3.5) IVR: -8.2 (-10.0 to -6.4) IVR + PC: -14.2 (-16.0 to -12.4) Overall P Value: < 0.001 UC: 0.02 UC vs IVR + PC: <0.001 IVR vs IVR + PC: <0.001 Diastolic BP (95% CI) Unadjusted mean UC: 85.7 (84.5 to 86.9) IVR: 84.5 (83.3 to 85.7) IVR + PC: 81.6 (80.4 to 82.9) Overall P Value: <0.001 UC: 0.18 UC vs IVR + PC: <0.001 IVR vs IVR + PC: <0.001 Adjusted mean change UC: -3.5 (-4.5 to -2.5) IVR: -4.4 (-5.4 to -3.4) IVR + PC: -7.0 (-8.0 to -6.0) Overall P Value: <0.001 UC: 0.21 UC vs IVR + PC: <0.001 IVR vs IVR + PC: <0.001 BP controlled (95% CI) unadjusted proportion UC: 0.31 (0.25 to 0.37) IVR: 0.36 (0.30 to 0.42) IVR + PC: 0.56 (0.49 to 0.62) Overall P Value: <0.001 UC: 0.20 UC vs IVR + PC: <0.001 IVR vs IVR + PC: <0.001 Adjusted RR UC: 1 IVR: 1.22 (0.95 to 1.56) IVR + PC: 1.84 (1.48 to 2.29) Overall P Value: <0.001 UC: 0.20 UC vs IVR + PC: <0.001 IVR vs IVR + PC: <0.001 | NS | NR | NR | At 12 mos after randomization Mean (SD) number of message threads UC: 2.4 (+4.6) IVR: 3.3 (±7.4) IVR + PC: 22.3 (±10.2) Mean (SD) number of patient initiated threads UC: 1.8 (±4.2), p = 0.01 IVR: 2.7 (±7.1), p <0.01 IVR + PC: 4.2 (±6.0), p <0.01 Mean (SD) number of telephone encounters UC: 4.0 (±4.8), p<0.001 IVR: 3.8 (±5.0), p<0.001 IVR + PC: 7.5 (±9.3) | NR | NR | Consumer Assessment of Healthcare Providers and Systems (Scale 0–10) Missing Data: 65 Baseline: 7.9 (±1.5) UC: 8.1 (±1.5) IVR: 8.1 (±1.5) IVR + PC: 8.3 (±1.4) Differences between IVR Groups, Mean Difference or RR (95% CI) UC vs IVR: 0 (-0.3 to 0.3) UC vs IVR + PC: 0.2 (-0.1 to 0.5) IVR vs IVR + PC: 0.2 (0 to 0.5) | NR | NR | Secondary Outcomes at 12 mos for all pts completing f/u in the electronic communications and home blood pressure monitoring trial; Mean (SD) QoL (1–100 scale) General health Missing Data: 38 Baseline: 67.1 (±20.4) UC: 66.7 (±20.4) IVR: 66.6 (±20.9) IVR + PC: 66.6 (±22.2) Differences between IVR Groups, Mean Difference or RR (95% CI) UC vs IVR: -0.1 (-4.0 to 3.7) UC vs IVR + PC: -0.1 (-4.0 to 3.8) IVR vs IVR + PC: 0 (-3.9 to 3.9) Physical health Missing Data: 44 Baseline: 80.6 (±27.0) UC: 78.1 (±27.7) IVR: 77.7 (±30.3) IVR + PC: 81.0 (±26.5) Differences between IVR Groups, Mean Difference or RR (95% CI) UC vs IVR: -0.4 (-5.6 to 4.7) UC vs IVR + PC: 2.8 (-2.3 to 8.0) IVR vs IVR + PC: 3.3 (-1.9 to 8.5) Emotional health Missing Data: 39 Baseline: 71.6 (±16.8) UC: 71.5 (±17.7) IVR: 72.1 (±16.8) IVR + PC: 71.7 (±19.7) Differences between IVR Groups, Mean Difference or RR (95% CI) UC vs IVR: 0.5 (-2.7 to 3.8) UC vs IVR + PC: 0.1 (-3.2 to 3.4) IVR vs IVR + PC: -0.4 (-3.7 to 2.9) | NR | UC (n=11) 4 withdrew 1 refused 2 could not be contacted 3 moved 1 other IVR (n=13) 8 withdrew 1 could not be contacted 2 missed visit 2 died IVR + PC (n=24) 8 withdrew 5 could not be contacted 4 missed visit 4 left health plan 2 too ill 1 died | NR | Secondary Outcomes at 12 mos for all pts completing f/u in the electronic communications and home blood pressure monitoring trial; Mean (SD) # of antihypertensive medication classes Missing Data: 0 Baseline: 1.64 (±0.85) UC: 1.69 (±0.91) IVR: 1.94 (±0.91) IVR + PC: 2.16 (±0.93) Differences between IVR Groups, Mean Difference or RR (95% CI) UC vs IVR: 0.3 (0.1 to 0.4) UC vs IVR + PC: 0.5 (0.3 to 0.6) IVR vs IVR + PC: 0.2 (0.1 to 0.4) Aspirin use, No. (%) Missing Data: 38 Baseline: 338 (±48.8) UC: 124 (±53.0) IVR: 131 (±56.0) IVR + PC: 149 (±66.5) Differences between IVR Groups, Mean Difference or RR (95% CI) UC vs IVR: 1.1 (0.9 to 1.2) UC vs IVR + PC: 1.3 (1.1 to 1.5) IVR vs IVR + PC: 1.2 (1.0 to 1.4) Body mass index Missing Data: 34 Baseline: 32.3 (±6.5) UC: 32.5 (±6.5) IVR: 32.5 (±7.0) IVR + PC: 31.6 (±6.2) Differences between IVR Groups, Mean Difference or RR (95% CI) UC vs IVR: 0 (-1.1 to 1.2) UC vs IVR + PC: -0.9 (-2.1 to 0.3) IVR vs IVR + PC: -0.9 (-2.1 to 0.3) Active, No. (%) Missing Data: 49 Baseline: 464 (+68.1) UC: 158 (±68.4) IVR: 173 (±73.9) IVR + PC: 155 (±71.8) Differences between IVR Groups, Mean Difference or RR (95% CI) UC vs IVR: 1.1 (1.0 to 1.2) UC vs IVR + PC: 1.0 (0.9 to 1.2) IVR vs IVR + PC: 1.0 (0.9 to 1.1)
Guendelman | 2002 | Children's hospital | Children's hospital | Homes | RCT | N = 134 Grp 1: 66 Grp 2: 68 | April 1999–July 2000 | 3 mos | *Ages 8–16 years old *English speaking caregiver telephone at home *Diagnosed with persistent asthma following NHLBI clinical practice guidelines | Involved in another asthma or drug efficacy trial Involved in research requiring behavioral modification If they had mental or physical challenges that made it difficult to use the system Co morbid conditions affecting quality of life | NR | YES: children, mostly Medicaid population | ASTHMA | NR | Grp 1: 61% Grp 2: 54% | Mean (Range): 12 (8–16) | Grp 1 Caucasian: 8% African-American: 79% Grp 2 Caucasian: 12% African-American: 74% | NR | Of the primary caregiver ≤HS Grp 1: 39 % Grp 2: 51% Some College Grp 1: 61% Grp 2: 49% | NR | NR | Public Health Insurance Grp 1: 92% Grp 2: 93% | English speaking caregiver | NR | NR | Health Buddy | Interactive communication device with question and response tasks. Questions provided by the nurse to the patient for their response | Group 1: Intervention group that used Health Buddy Group 2: Control group | Website | Education, information sharing, advice sending | NR | Those assigned to the Health Buddy were given a demonstration on how to use the device and explained how to install it at home | NR | NR | Any urgent calls (Baseline vs. 12 week follow-up) - (P=0.05) Grp 1: 32% vs. 10% Grp 2: 22% vs. 15% ED visit (baseline vs. 12 week follow-up) - (P=0.21) Grp 1: 27% vs. 10% Grp 2: 28% vs. 18% Any hospitalizations (baseline vs. 12 week follow-up) - (P=0.96) Grp 1: 14% vs. 6% Grp 2: 13% vs. 2% | NR | NR | NR | NR | NR | NR | NR | NR | Limitation in activity (baseline vs. 12 week follow-up) - (P=0.03) Grp 1: 67% vs. 32% Grp 2: 72% vs. 47% Trouble sleeping (baseline vs. 12 week follow-up) - (P=0.83) Grp 1: 62% vs. 34% Grp 2: 59% vs. 27% Missed school (baseline vs. 12 weeks follow-up) - (P=0.41) Grp 1: 52% vs. 15% Grp 2: 44% vs. 22% | NR | 12 participants (4 in Grp 1 and 8 in Grp 2) did not complete the 12 week follow-up Reasons included: moving or life crisis events within the family, 5 were lost to follow-up | NR | NR
Gustafson | 1999 | HIV clinics and organizations in Wisconsin | NR | Homes | Randomized trial | N = 204 IVR: 107 CG: 97 | NR | 3 to 6 months implementation with 2–3 month follow-up (total 5 to 9 months) | *Pt has HIV | Dementia, living with subject in experimental condition, living situation prohibiting computer installation, disappearance | NR | NR | HIV | NR | Exp: 90.9% CG: 89% | Mean (SD) Exp: 34.8 CG: 34.1 | Caucasian Exp Grp: 81.2% CG: 86.7% | NR | Mean years Exp Grp: 14.3 CG: 14.7 | NR | Employed Exp Grp: 53.1% CG: 44.4% | Insured Exp Grp: 75.8% CG: 80.5% | NR | NR | NR | CHESS | Computerized information, decision support, expert | NR | Computer and Internet | Online library, referral directory, assessment, decision aid, action plan, discussion group, ask an expert, personal stories | NR | NR | NR | NR | Similar ambulatory and emergency visits; higher phone calls in Exp group Lower hospitalization in Exp group: 0.14 per subject Control: 0.21 per subject (p=.02) | NR | NR | NR | NR | NR | NR | NR | NR | Exp group self-reported significantly improved cognitive function, negative emotions, active life and social support Improvements persisted in social support and participation in healthcare 3 months after subjects had 6 months of CHESS | NR | NR | NR | NR
Gustafson | 1994 | HIV & AIDS outpatients (no recruitment details) | NR | Homes | RCT | N = 204 IVR: 107 CG: 97 | 1992-1993 | 5 months of use, 3 months post use for subset 30 INT/28 CTRL | NR | NR | NR | NR | HIV/AIDS | NR | NR | NR | “Minorities:” 39/204 (19.1%) | NR | NR | NR | NR | NR | NR | NR | NR | CHESS | 9 services for information, support, problem solving | NR | PC w/ modem | Information, social and emotional support, problem solving, in 9 modules | NR | NR | NR | NR | Self report visits same; calls to clinic higher; post study self report visits fewer; visit time less; admissions problem 16% v 42% ctrl (NS); LOS 61% higher ctrl, 29% lower interest | NR | NR | 15966 uses/116 subjects, ~39 hrs/138 uses each; 73% in Discussion Group, 17% in Info Svc, 2% in Problem Solving | NR | NR | NR | NR | No change in risky behavior, improved attitude about reporting HIV status | Improved 5 of 8 dimensions: social support, cognitive fxn, active life | NR | NR | NR | NR
Gustafson | 2001 | Urban, small city and rural areas | 2 Teaching hospitals; 2 Non-teaching hospitals and a cancer resource center | Homes | RCT | N= 295 Grp 1 (CHESS): 136 Grp 2 (Control): 132 N= 246 Grp 1: 121 Grp 2: 125 | 2 yrs (April 1995–May 1997) | 5 months | *Pts were within 6 months of diagnosis *Age <=60 *Not homeless *Not active illegal drug users *Able to give informed consent *Able to understand and answer sample questions from the pre-test survey | Patients treated in small, rural general surgeries were excluded | NR | YES: the two non teaching hospitals and the cancer resource center were catering to underserved population | BREAST CANCER | NR | N = 0% | Mean (SD): Grp 1: 44.3 (±6.6) Grp 2: 44.4 (±7.1) | Caucasian Grp 1: 76% Grp 2: 72% | Income (annual: ≥$ 40,000) Grp 1: 58.1% Grp 2: 50.8% | Bachelor's degree Grp 1: 45.8% Grp 2: 40.2% | Urban, small city and rural areas | Living with partner, (%) Grp 1 vs. Grp2 71.9 vs. 72.6 Days since diagnosis At pretest; Mean (SD) ; Grp 1 vs. Grp 2 ; 55.0 (±36.3) vs. 47.4 (±32.6) Stage : Early- I or II, (%); Grp 1 vs. Grp 2; 81.9 vs. 78.9 Surgery: Mastectomy,(%); Grp 1v s Grp 2; 55.4 vs. 60.0 Chemotherapy; (%); Grp 1 vs. Grp 2; 54.5 vs. 51.2 Radiation, (%); Grp 1 vs. Grp 2; 38.0 vs. 40.8 | Private insurance Grp 1: 86% Grp 2: 84.7% | NR | NR | NR | CHESS | Computer based patient support system providing information, decision-making and emotional support | Grp 2 (Control): Pts were given a copy of Dr. Susan Love's Breast Book Grp 1 (CHESS): had use of this for 6 months, were trained briefly and had a user's manual. CHESS description *Information system had short answers to frequently asked breast cancer questions, instant library with articles from scientific and popular press, consumer guide with description of health services, identifying good providers and the like, Referral directory with descriptions of and ways to contact local and national breast cancer services Support services had discussion groups (limited access, facilitated bulletin boards for sharing information and support), ask an expert with confidential responses, and personal stories of others coping with the same problem Decision services included assessment of pts's emotional status and offers coping advice, health charts that has patients record and track health changes, decision aids that help in learning about options, clarify values and understand consequences of choices and action plan that identifies goals, resources and ways to overcome obstacles. | Computer | Forums, question and answers, library, expert communication, action plan | NR | Grp 1 pts were briefly trained on how to use CHESS | NR | NR | NR | NR | NR | NR | NR | Participation- Level of comfort Grp 1vs Grp2 Means (covariate adjusted); Difference between means ; CHESS -Control (95% CI) 2 months- 80.7 vs. 74.3 ; 6.4 (2.1 to 10.7), p < 0.01 5 month-79.1 vs. 76.5; 2.6 (-1.4 to 6.7) Confidence in doctors Grp 1vs Grp2 Means (covariate adjusted); Difference between means ; CHESS -Control (95% CI) 2 month - 83.0 vs. 77.3, 5.7 (1.0 to 11.3), p < 0.05 5 month- 82.8 vs. 79.0, 3.8 (-2.2 to 9.8) Information competence Grp 1vs Grp2 Means (covariate adjusted); Difference between means ; CHESS -Control (95% CI) 2 months- 70.4 vs. 65.6 ; 4.8 (1.5 to 8.1), p < 0.01 5 month - 69.3 vs. 65.8; 3.5 (0.0 to 6.9), p= 0.05 Unmet information need Grp 1vs grp2 Means (covariate adjusted); Difference between means ; CHESS -Control (95% CI) 2 months- 70.0 vs. 67.2 ; 2.8 (- 2.7 to 8.4) 5 month - 67.0 vs. 69.6 ; - 2.6 (- 8.2 to 2.9) | NR | NR | Participation- behavioral involvement Grp 1vs Grp 2 Means (covariate adjusted); Difference between means; CHESS -Control (95% CI) 2 months: 75.6 vs. 73.1; 2.5 (- 1.1 to 6.1) 5 month: 74.5 vs. 72.8; 1.7 (-2.3 to 5.6) | Social/Family well being Grp 1vs grp2 Means (covariate adjusted); Difference between means ; CHESS -Control (95% CI) 2 months- 79.3 vs. 78.2; 1.1 (-3.0 to 5.4) 5 month - 75.8 vs. 74.7; 1.1 (- 3.3 to 5.5) Emotional well being Grp 1vs grp2 Means (covariate adjusted); Difference between means ; CHESS -Control (95% CI) 2 months- 73.9 vs. 72.8 ; 1.1 (- 3.1 to 5.2) 5 month - 76.3 vs. 75.3; 1.0 (-3.0 to 5.0) Functional well being Grp 1vs grp2 Means (covariate adjusted); Difference between means ; CHESS -Control (95% CI) 2 months- 62.2 vs. 63.0 ; - 0.8 (- 5.3 to 3.6) 5 month - 70.4 vs. 69.9 ; 0.5 (-3.5 to 4.4) Breast cancer concerns Grp 1vs grp2 Means (covariate adjusted); Difference between means ; CHESS -Control (95% CI) 2 months- 65.1 vs. 63.3 ; 1.8 (- 1.9 vs. 5.5) 5 month - 67.6 vs. 64.7 ; 2.9 (-0.6 to 6.4) | Social support Grp 1 vs. Grp 2 Means (covariate adjusted); Difference between means ; CHESS -Control (95% CI) 2 months: 80.8 vs. 78.4 ; 2.4 (- 1.2 to 5.9) 5 month: 84.2 vs. 79.3; 4.9 (1.4 to 8.4) | Patient's recruited: 296 Withdrew before randomization: 1 Randomized: 295 Control: 148, CHESS: 147 Out of control group Withdrew before start of study: 16 Participated: 132 Out of 132 that participated, Dropped from study: 7 Completed trial, five month survey: 125 Out of CHESS group Withdrew before start of study: 13 Died before start of study: 1 Participated: 133 Out of 133 that participated, Dropped from study: 12 (Died during study=3, Lost to follow up=9) Completed trial, five month survey: 121 | NR | Recruitment rates in the different places given, not listed here Reasons for refusal to participate among patients contacted also given Measurement issues discussed, not listed here The author mentions that their sample size of 246 subjects at an alpha= 0.05 provided a 0.80 power to detect a 0.36 SD difference between the CHESS and control groups. The author has also discussed interactions with indicators of medical under service, not listed here
Gustafson | 1998 | 5 Wisconsin counties | Surgeons at 12 clinics, 10 hospitals, 7 HMOs | Homes | NR | N = 38 | 1997 | 10 weeks | *Elderly women with breast cancer *Medicare eligible *Diagnosis w/in 4 months *Able to read and provide informed consent *No dementia | NR | YES | NR | BREAST CANCER | NR | N = 0% | Mean (SD): 71.8 (±6.06) | NR | NR | NR | Potentially eligible urban: 28pts (76%) Rural: 10 pts (71%) | 63% living alone, 58% had co morbidities, 5.3% had metastic breast cancer, 37% had computer experience | NR | NR | English | NR | CHESS | NR | NR | Website | Provides patient education through a home PC, given articles, tutorials about services, anonymous access to experts, monitor health status, help making decisions | NR | NR | NR | NR | NR | NR | NR | Service, Number/% of uses, Number/% of patients using service Discussion group: 743/33.9%, 38/100% Ask an expert: 374/17.1%, 38/100% Questions and answers: 287/13.1%, 38/100% Health Charts/profiles: 214/9.7%, 38/100% Instant Library: 161/7.3%, 32/85% Personal stories: 138/6.3%, 36/95% Consumer guide/referral: 75/3.4%, 29/76% Decision Analysis: 97/4.4%, 30/79% Stress Management: 52/2.4%, 18/48% Action Plan: 51/2.4%, 20/52% | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Hoch | 1999 | NR | NR | NR (Homes) | Descriptive | N = 497 Posts: 155 Responses: 342 | 1995-1998 | NR | NR | NR | NR | NR | EPILEPSY | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | MGH Neurology Epilepsy Web forum | Open web forum | NR | Computer | Forum | NR | NR | NR | NR | NR | NR | NR | Questions Caregivers: 42% Patients: 35% Providers: 2% Unidentified: 21% Answers Caregivers: 34% Patients: 38% Providers: 6% Unidentified: 22% | NR | NR | NR | NR | NR | NR | NR | NR | 6% inaccurate responses | NR
Holman | 1996 | Diabetic patients | Diabetes clinic | Homes | Randomized cross-over design | N= 6 | NR | NA | *Diabetic patients | NR | NR | NR | DIABETES | NR | N = 67% | Mean (SD): 33.8 (±11.7) | NR | NR | NR | NR | Duration of diabetes years: 12.7 (±10.9) HbA_1_: 9.3% | NR | NR | English | NR | Patient-oriented, insulin regimen optimizer (POIRO) | Hand held computer to record prep radial glucose level, expected meal size, expected exercise, health level and hypoglycemic episodes, and to recommend correct insulin dose | Cross-over design: each participant had two consecutive three week study periods, with and without the computerized insulin dose advice switched on, in a randomly allocated order. Training: one week lead in period of recording glucose levels. Patients were given written instructions and a 24 hour contact number | Hand-held computer | Provide recommended insulin dose based on patient entered glucose level, size of meal, exercise, health and severity of hypoglycemic episodes | NR | NR | NR | Advice On vs. Advice Off: mean (SE) Pre-prandial glucose: 8.9 (±0.4) vs. 7.5 (±0.4); p=.015 Fructosamine: 492 (±34) vs. 481 (±34); NS HbA1: 9.2 (±0.5) vs. 9.2 (±0.5); NS | NR | NR | NR | NR | NR | Data NR. All the patients said that they had found POIRO easy and convenient to use | NR | Data NR. Reported text says most patients felt more confident about changing their insulin dose | NR | NR | NR | Total: 1 patient. 16% Primary reason: domestic issues unrelated to the trial Additional factor: disappointment that POIRO “failed to prevent a hypo” | NR | Ultralente insulin dose, soluble insulin dose, number of patients with hypoglycemia, number of hypoglycemic episodes
Jan | 2007 | Specialty clinic | Specialty clinic, university medical center | Homes | RCT | N = 164 IVR: 88 CG: 76 | 2004 | 3 months | *Internet access *“Persistent asthma” | Chronic co morbidity such as bronchopulmonary dysplasia | NR | NR | ASTHMA | NR | IVR: 35% CG: 28% | Mean (SD) IVR: 10.9 (±2.5) CG: 9.9 (±3.2) | Chinese | NR | NR | Urban | NR | NR | NR | NR | NR | Blue Angel for Asthma | Education, monitoring, self-management advice-not entirely clear how tailored | CG: symptom and spirometry diary, guideline based self management education IVR: internet based symptom and spirometry diary, guideline based self management education, physician advice by email or phone | Computer | Education, monitoring, self-management advice - not entirely clear how tailored | NR | Family instructed in use of website | NR | PEF: NS (better mean INT, better median CTRL) | NR | NR | Asthma knowledge IVR: 93% CG: 70% | NR | NR | INT satisfied w/ program, controls not asked | NR | NR | Monitoring adherence fell 96 to 83 IVR vs. 93% to 53% CG Change in peak flow technique NS Spacer use NS Steroid use fell 83% to 63% IVR, 82% to 42 CG | Asthma control ‘well controlled’ 52 IVR: 52% to 62% CG: 40% to 42% QoL no difference | NR | Withdrew on request or tech failure IVR: 9 (9%) CG: 6 (7%) Did not return at 12 wk IVR: 6 CG: 5 | NR | Symptoms: improved, but floor effect w/ CNTRLs
Japuntich | 2006 | General population via billboards, bus posters, flyers, TV ads and press releases | Center for Tobacco Research and Intervention | Homes | RCT | N= 284 Control: 144 CHESS SCRP: 140 | October 2001 – July 2002 | 12 mos | *Age ≥18 yrs *Smoking at least 10 cigarettes per day *Having a traditional telephone line *Literate in English | Current depression, current use of psychiatric medication, medical conditions contraindicating bupropion SR use (e.g., history of seizure disorder), current use of a smoking cessation product or treatment, or being pregnant or likely to become pregnant during the treatment phase of the study | NR | NR | SMOKING | NR | CG: 45.1% CHESS SCRP: 45% | Mean (SD) CG: 41.0 (±11.8) CHESS SCRP: 40.6 (±12.4) | Not Caucasian CG: 17.4% CHESS SCRP: 24.6% | NR | Control Group: Less than high school: 2.8% High school or GED: 27.8% Some college or tech school: 47.2% College or graduate school: 21.5% CHESS SCRP: Less than high school: 3.6% High school or GED: 29.5% Some college or tech school: 51.8% College or graduate school: 15.1% | NR | # of cigarettes per day: Mean (SD): Control: 22.1 (±11.8) CHESS SCRP: 21.1 (±9.5) Years smoking: Mean (SD): Control: 23.3 (±12.3) CHESS SCRP: 22.7 (±12.1) Number of quit attempts: Mean (SD): Control: 6.1 (±11.1) CHESS SCRP: 5.4 (±12.5) | NR | English literate | English | NR | Comprehensive Health Enhancement Support System for Smoking Cessation and Relapse Prevention (CHESS SCRP) | Intensive internet intervention to provide information, emotional support and problem-solving assistance. Four sections. First section provides information about quitting smoking. Second section is a support center that provided chat programs as well as a cognitive behavioral therapy intervention for negative emotions. Third section was an information repository. Fourth section allowed participants to search for information within CHESS SCRP, a list of recommended websites, and tips for evaluating other websites. | Control Group: 9 weeks of twice daily buproprion SR (150mg), three brief individual counseling sessions, and five follow-up visits CHESS SCRP: all of the above + 12 weeks of access to the CHESS SCRP website Participant training: in- home training session for use of computers and the specific website. | CHESS SCRP website | Information on quitting smoking, chat/discussion groups, ask-an-expert service, self-therapy for bad moods, journal (structured and unstructured), document storage, additional recommended websites, advice for evaluating other websites | Staff explained basic computer used if necessary. Staff demonstrated all of the CHESS SCRP services and showed where they were located within the website. | NR | 9 weeks of twice daily buproprion SR (150mg); 3 individual counseling sessions, five follow-up visits | None | NR | NR | NR | Over 12 week intervention period: Number of log-ins Mean: 33.6 (±30.8), Median: 24 Minutes logged on Mean: 486.4 (±638.9), Median: 202.9 Most popular services Support tools: Mean: 43.29 min (±109.81) Reading discussion group postings: Mean: 24.70 min (±116.13) Least popular services Information tools: Mean: 7.97 min (±18.41) Use not correlated with gender, race, education Use was correlated with age: Mean (SD) logins per week: 18–35: 2.02 (±1.53) 34–45: 2.18 (±2.54) ≥ 46: 3.35 (±2.57) | NR | NR | NR | Center for Epidemiological Studies Depression Scale (CES-D): measure used, Data NR | Fagerstrom Test for Nicotine Dependence (FTND) collected, Data NR Logistic Regression: use predicts 3 and 6 month abstinence levels (use transformed into 4 discreet categories of logins per week): 3 month: OR: 1.79, 95%CI 1.25–2.56 6 month: OR: 1.59, 95%CI 1.06–2.38 When controlling for # of past quit attempts, longest period of abstinence in the past, how much success the participant expected in this quit attempt, age, and dependence as measured by the FTND: still significant: 3 month: OR: 2.10 95%CI 1.36–3.25 6 month: OR: 2.13 95%CI 1.25–3.61 Cessation rates: ns by gender, education, race/ethnicity. Differed by age at 3 months (OR=1.026, 95%CI 1.002–1.05), ns at 6 months Relapse prevention: access to CHESS SCRP to predict abstinence at 3 or 6 months: ns trend: 3 month: OR: 1.07, 95%CI .54–2.14 6 month: OR: 1.66, 95%CI .76–3.63 | NR | NR | All dropouts considered smokers in analyses. CHESS SCRP: 13.6% due to missed appointments; 15% withdrew before 1 year follow-up (reason NR); 19.3% lost to follow-up. Control: 22.2% withdrew before 1 year follow-up (reason NR); 20.8% lost to follow-up. | NR | NR
Jones | 1999 | Referred for radiotherapy of breast, prostate, larynx or cervical cancer | Radiotherapy clinic | In Clinic | RCT | N = 525 BKLT: 180 GINF: 167 PINF (personalized by EHR): 178 | 1996-1997 | 3 months | *Referred for radiotherapy of breast, prostate, larynx or cervical cancer | Severe symptoms, palliative care, unaware of dx, cognitive or visual disability | Yes: Over 60 examined as variable | YES: “deprivation category” by external reference | CANCER | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | Personalized computer based information | Cancer information tailored by data in EHR vs. not tailored vs. printed booklets | Tailored (PINF) vs. non-tailored (GINF) vs. choice of 143 printed booklets (BKLT) | Computer | Education | NR | NR | NR | NS change depression and cancer adjustment scores; 84% improved anxiety scores, especially PINF, especially but also BKLT; subgroups examined | NR | NR | Physician assessed ‘above avg knowledge’ 35% GINF, 25% PINF, 20% BKLT. [note that in general, docs assessed pt knowledge below average] | 12 min (1–44) 1st use; 71% no repeat use: 20/169 PINF, 4/155 GINF | NR | 80% would prefer 10 min w/professional (71% PINF, 80% GINF, 90% BKLT) Overall 40% satisfied Satisfaction with information higher in PINF | NR | NR | NR | NR | NR | NR | NR | Cost of intervention calculated less compared to printed booklets at £7 per patient
Jones | 2001 | Community practice | NR | Home, Community resource center | RCT | N = 112 Computer: 56 Psych Nurse: 28 Both: 28 | NA | 3 months | *ICD-10 diagnosis of schizophrenia *Living in southern Glasgow | Age > 65 yrs, had an uncertain diagnosis, judged acutely ill, chronic problems restricting participation, recent participation in an educational program. | NR | NR | SCHIZOPHRENIA | NR | N = 67% | Range: 18 to 65 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | Computer: 5 web-based sessions giving general information, personal information from medical record, feedback displays; Psych nurse: 5 in-person sessions (1 hour); Both: computer plus psych nurse Computer program sessions Psychiatric nurse sessions Both computer and nurse sessions | NR | WWW | NR | Researcher trained subjects on computer use | NR | NR | NR | NR | Costs (£) of each intervention arm were estimated (ITT analysis), Computer vs. Nurse vs. Both (includes time + travel): Staff costs: 138.4, 107.9, 139.8; Patient costs: 14.2–32, 12–28, 17–38 | NR | Time on computer sessions: Median: 69 minutes Range: 34–143 | Of 39 subjects completing 1st session Touch screens easy to use: 27 Touch screens OK to use: 9 Touch screens difficult to use: 3 One-third were uncertain about what to do following a display. | Computer vs. Nurse vs. Both Sessions useful: 67% vs. 75% vs. 60% Information relevant: 75% vs. 100% vs. 60% Enjoy sessions: 72% vs. 92% vs. 75% Enough information: 63% vs. 83% vs. 75% Illness description understandable: 59% vs. 58% vs. 60% Wanted information but not obtained: 12% vs. 33% vs. 35% Got information not wanted: 38% vs. 58% vs. 55% Mean satisfaction (0–10): 5.5 vs. 7.2 vs. 6.2 | NR | NR | NR | NR | NR | Randomized vs. Complete Data (N): Computer: 56 vs. 34; Nurse: 28 vs. 20; Both: 28 vs. 13 | NR | Psychological Measures: Computer vs. Nurse vs. Both: Multiple measures used (BPRS, ITAQ, GAF, KISS) showed no difference across groups. % of patients with improved KISS scores (Knowledge and information about schizophrenia schedule), 1st to 3rd (3 month) interviews: 39%, 21%, 50%, p=.08
Joseph | 2007 | Urban high schools | NR | Schools | RCT | N=314 IVR: 162 CG: 152 | NR | 12 months | *Met study criteria for current asthma (defined as report of ever having a physician diagnosis of asthma accompanied by one or more of the following; - daytime and/or nighttime symptoms in the past 30 days; - use of medication symptoms for asthma in the past 30 days,; - medical care use for asthma in the past year one or more refills of B-agonists in the past year); Not reporting a physician diagnosis but answered positively to items from ISAAC and reported symptom frequencies similar to those used in EPR 2 for classification of mild intermittent asthma | NR | NR | YES: urban African-American youth | ASTHMA | NR | N = 36.6% | Mean (SD): 15.3 (±1.0) | African American: 98% | NR | High school students | Urban high schools | 52% qualities for federal school lunch program. Demographic information of non- participants given, not listed here | 49% Medicaid enrollees | NR | NR | NR | Puff city | web based program focusing on controller medication adherence, rescue inhaler availability, smoking cessation/reduction. Consists of 4 consecutive educational sessions making use of normative and impassive behavior. Voiced over messages (accommodates low literacy). Participant specific information obtained at baseline and 4 sessions and used for tailoring Theory based health messages and info on asthma control presented in reference to he 3 core behaviors mentioned above. e.g. info on basic asthma pathophysiology, trigger avoidance, correct use of metered dose inhaler and other devices. | IG- web based tailored program as described above. CG- students in this grp were directed to existing generic asthma educational websites. Students restricted to these sites and could not access links for outside programs or general interest sites. 4 computer sessions just like IG each of 30 mins For both IG and CG, a program module including names and illustrations of asthma medications were used to facilitate identification of current usage. A health care referral coordinator proactively contacted the students in the treatment group depending upon the risk assessment report that had key questions indicating need for assistance (possible depression, severe and persistent asthma attack, sharing medication, lack of physician, lack of inhaler etc). The coordinator did not initiate contact with students in the control group, except in potentially high risk situations. | Computer | Education, answering questions | NR | NR | NR | Grp 1 vs. Grp 2 Adjusted RR (95% CI) Symptom days(2 wks) 2.1 (±3.0) vs. 2.8 (±3.4) 0.5 (±0.4–0.8); p= 0.003 Symptom nights/2 wks 0.9 (±2.3) vs. 1.5 (±2.5) 0.4 (±0.2–0.8); p= 0.009 School days missed/30 days 0.4 (±1.2) vs. 1.2 (±3.3) 0.3 (±0.1–0.7), p= 0.006 Days restricted activity/2 wk 1.3 (±2.2) vs. 2.3 (±3.4) 0.5 (±0.3–0.8), p= 0.02 Days had to change plans 0.4 (±1.2) vs. 0.6 (±1.5) 0.5 (±0.3–1.2), p= 0.17 | Grp 1vs Grp 2 Adjusted RR (95% CI), p Hospitalizations/12 months 0.2 (0.6) vs. 0.6 (2.0) 0.2 (0.2–0.9); 0.01 ED visits/12 months 0.5 (2.0) vs. 0.8 (1.9) 0.5 (0.3–1.3); 0.08 | Estimated labor costs for the referral coordinator was $ 6.66/treatment student ($8.05 per treatment student referred, $11.73 per student contacted) | NR | NR | NR | NR | NR | NR | Controller medication adherence, % (n), Positive behavior Grp 1 vs. Grp 2 20.4 (31) vs. 12.6 (18), p— 0.09 No change in negative behavior Grp 1 vs. Grp 2 62.5 (95) vs. 63.6 (91), p—? Negative change in behavior Grp 1 vs. Grp 2 17.1 (26) vs. 23.8 (34), p—? Rescue inhaler activity, % (n) Positive behavior Grp 1 vs. Grp 2 38.8 (59) vs. 32.2 (46), p—0.01 ? no change in negative behavior Grp 1 vs. Grp 2 48.7(74) vs. 43.3(62) Negative change in behavior Grp 1 vs. Grp 2 12.5(19) vs. 24.5(35) Smoking cessation/reduction, % (n) Positive behavior Grp 1 vs. Grp 2 95.0 (132) vs. 94.1 (111), p= 0.89? No change in negative behavior 0.7(1) vs. 0.8(1) Negative change in behavior 4.3 (6) vs. 5.1(6) | Cumulative score Grp 1 vs. Grp 2 5.3 (±1.3) vs. 5.0 (±1.5) RR (95% CI) 1.2 (0.9–1.6), p=0.35? Activity domain Grp 1 vs. Grp 2 5.3 (±1.7) vs. 5.0 (±1.7) RR (95% CI) 1.4 (1.0–2.0), p= 0.16 Emotional domain Grp 1 vs. Grp 2 5.7 (±1.5) vs. 5.3 (±1.6) RR (95% CI) 1.2 (0.9–1.7), p-0.38 Symptom domain Grp 1 vs. Grp 2 5.3 (±1.6) vs. 4.9 (±1.6) RR (95% CI) 1.4 (1.0–1.9), p— 0.07 | NR | Out of 350 pts who returned consent forms, Baseline incomplete: 36 Out of this 36 Transferred: 14 Moved: 3 12th grade: 1 Other reasons: 18 | NR | Flowchart of study participation and randomization given Comparison of eligible students by study participation using results of the lung health survey given, not listed here Study compliance, status of core behavior, report of controller and rescue medication at session 1 by randomization grp given, not listed here Reasons for contact with referral coordinator and the no of students meeting the coordinator in both grps given, not listed here
Kashem | 2006 | NR | HF practice at Temple University medical center | Homes | RCT | N= 36 Grp C (control): 18 Grp T (telemedicine): 18 | NR | 8 months | *Pts with NYHA class 2,3 or 4 Heart failure (HF) and at least 1 HF admission within the past 6 months *All pts required to have telephone and internet access *Be able to read and write *Know basic skills of computer use and internet navigation | NR | NR | NR | CHF | NR | Control: 66.7% Telemedicine: 72.2% | Control: 55.1 (±12.6) Telemedicine: 52.2 (±10.6) | Control vs. telemedicine, (%) Caucasian: 66.7 vs. 72.2 African American: 27.8 vs. 27.8 Latino/Hispanic: 5.6 vs. 0 | NR | NR | NR | Grp C vs. Grp T Weight (pounds): 206.1 (±66.5) vs. 202.4 (±47.7) BMI: 32 (±12.6) vs. 30.4 (±6.9) Systolic BP: 119.1 (±17.7) vs. 97.8 (±7.2) Diastolic BP: 70.5 (±7.5) vs. 61.7 (±3.4) Ejection fraction (%): 26.6 (±16.4) vs. 23.9 (±17.6) NYHA (%): Class 2: 42.9 vs. 42.1 Class 3: 52.4 vs. 57.9 Class 4: 4.8 vs. 0 Cardiomyopathy etiology (%) Ischemic: 44.4 vs. 50 Dilated: 38.9 vs. 38.9 Other: 16.7 vs. 11.1 | NR | NR | NR | NR | Insight Telehealth systems | Evaluation of web based internet telemedicine management system for reducing care encounters in heart failure patients | Grp T: pts reported three times weekly via a secure internet site for telemedicine intervention; received present standard care provided by the advanced HF and cardiomyopathy team. Pt use of the system: The pt can enter data regarding weight, steps per day with pedometer, blood pressure and heart rate (daily or several days' data can be entered in one login session); the pt can review their data by trend charts and numerical tables displayed on the computer screen; medication screen allows pt or provider to enter medication (each record includes dose, administration schedule, ordering physician, and date of prescription expiration); pt can review his/her medication, dose, frequency, physician and prescription information. Provider use of the system: data for 10–15 pts are presented simultaneously on one screen, color coded red data represents values outside preset limits, possible to send text messages to the pt or short message stating that his/her values are acceptable Grp C: received the present standard care provided by the advanced HF and cardiomyopathy program. | Computer | Data entry, review of charts, numerical tables, prescription information, messages between pt and health care provider | NR | All pts given sphygmomanometer and pedometer and instructed how to use them, pt made first time data entry with coaching by a research nurse | NR | NR | Control vs. Telemedicine Clinic phone calls: 21 vs. 39, p= 0.025 Scheduled clinic visits: 7 vs. 11, NS Unscheduled clinic visits: 5 vs. 3, NS Hospitalizations (number): 18 vs. 9, p= 0.025 Hospital days: 133 vs. 44, p= 0.030 | NR | NR | Interactions Data sent by the patients: 1,253 Text messages sent by the patient: 362 Generic messages sent by the provider: 836 Tailored text messages sent by the provider: 416 Total number of internet interactions: 2,867 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Kaufman | 2003 | Diabetic outpatients | Medical center | Homes | Usability cognitive walkthrough and field observation | N = 25 NYC: 14 Upstate: 11 (but really 2 case studies) | NR | NA | *Patient volunteers *Selected segments based on log files *Contrasted 2 cases at extremes | NR | YES | YES: rural upstate NY and Hispanic NYC | DM | NR | NR | Mean (SD) NYC: 69.6 (±6) Upstate: 73.7 (±8) | Hispanic: 14pts Caucasian: 11pts | NR | Mean years (SD) NYC: 8.5 (±5) Upstate NY: 12.1 (±3) | NR | NR | NR | NR | Spanish: 12 English: 13 | NR | IDEATel | Videoconferencing, BP & BG uploading and review, education, email | Novice users of system | Computer | Education, monitoring, videoconferencing, | NR | Ongoing | NR | NR | NR | NR | NR | NR | System barriers: problematic widgets, small fonts, bad spacing, complex tasks, screen transitions, system stability Cognitive/Skill barriers: mouse-keyboard skill, mental model, literacy, numeracy. Also anxiety, self-efficacy, motivation | NR | NR | NR | NR | NR | NR | NR | NR | NR
Kenwright | 2005 | OCD patients | BTSteps clinic | Homes | Randomized trial | N=44 Requested Support: 22 Scheduled Support: 22 | NR | 17 weeks | *Diagnosed primary obsessive compulsive disorder (OCD) for at least 2 years | Schizophrenia, bipolar disorder, other psychosis, primary major depression, suicidal plans, alcohol or substance abuse. | NR | NR | OCD | NR | N = 47.7% | Mean: 40 Groups NR | NR | Unemployed: 45% | NR | NR | NR | NR | NR | NR | NR | NR | Live help-line support during office hours | Scheduled support: 9 therapist initiated phone calls at set appointments over the 17 weeks Requested support: patient-initiated calls when help was wanted | Phone | Help-line support | NR | NR | BT Steps: Phone system with user manual to guide individually tailored self-help for OCD. Uses Behavioral exposure therapy with ritual prevention (ERP). BTSteps guides traditional ERP in 9 steps. Steps 1–3 concern education and self-assessment, steps 4–9 guide daily self-exposure to triggers of rituals, obsessions, and discomfort, followed by self-imposed ritual prevention. IVR system helps users to identify triggers for rituals and obsessions and to set homework tasks that last at least 1 hour a day until discomfort falls for each trigger. | NR | NR | NR | NR | Therapist-Support Phone Time: Mean per patient duration of support calls: Scheduled: Mean: 13 minutes (Range 5–35 minutes) Requested: Mean: 11 minutes (Range 3–25 minutes) Mean total support time per patient: Scheduled: Mean: 76 minutes (±78); Mean # calls: 7.5 (±3.7) Requested: Mean: 16 minutes (±36); Mean # calls: 1.5 (±2.8) Mean per patient time spent calling BTSteps's IVR system: Scheduled: 232 minutes (±162) Requested: 178 minutes (±149) | NR | NR | NR | [underlined: Yale-Brown Obsessive Compulsive Scale (YBOCS):] Scheduled patients: significant improvements on YBOCS Total (t= 4.8, 95% CI= 4.6–113.6, effect size=1.2, p<.001,), YBOCS Obsessions (t= 4.8, 95%CI= 2.2–5.6, effect size, 1.0, p<.001), YBOCS Compulsions (t= 4.4, 95%CI= 2.2–6.1, effect size=1.1, p=.04) Requested patients: sig. improvement on YBOCS Compulsions (t= 2.0, 95%CI=.00–2.9, effect size=0.6, p=.04) Improvement significantly greater in Scheduled than Requested patients on YBOCS Total (F= 7.0, p=.01) and YBOCS Compulsions (F= 11.6, p=.001). ns for YBOCS Obsessions. [underlined: Treated Target Triggers:] discomfort during patients first two ERP homework tasks: Scheduled and Requested patients improved significantly, but difference ns (F=.917, p=.346) [underlined: Work and Social Adjustment]: Improvement greater for scheduled than requested patients on WSAS Total (F=3.2, df=1, p=.05) | NR | NR | NR | Scheduled: 13.6% Requested: 59.1% (2-tailed Fisher's exact test= 0.004) | NR | NR
Kenwright | 2004 | NR | Computer aided self-help clinic | Homes/clinic | Cohort | Home internet=10 London clinic= 17 | Dec 2000 to Dec 2001 | 1 month | *Presence of phobia or panic disorder (based on an interview checklist of ICD-10 diagnostic criteria; WHO, 1992) *Motivation to try self- help *Absence of substance misuse, psychosis or active suicidal plan | NR | NR | NR | PHOBIA/PANIC DISORDER | NR | Home internet vs. London clinic 60% vs. 52.9% | Home internet vs. London clinic 37 yrs vs. 36 yrs | NR | NR | NR | NR | Condition; Home internet Agoraphobia with panic= 6 Social phobia=3 Insect phobia and Claustrophobia=1 Co morbid conditions=5 (depression=3, Generalized anxiety disorder=2) London clinic Specific phobia=7 Agoraphobia with panic= 5 Social phobia=4 Generalized anxiety disorder=2 Obsessive compulsive disorder= 1 Mean problem severity Home internet vs. London clinic= 6 vs. 5.4 Employed full time Home internet vs. London clinic= 5 vs. 13 Home internet vs. London clinic Used computers more often= 5 vs. 5 Occasionally used computers= 3 vs. 7 Hardly/never used computers=2 vs. 5 | NR | NR | NR | NR | FearFighter | Computer sided exposure self help system at home on the internet with brief therapist support by phone | Home internet- unlimited access to fearfighter on the internet for 12 weeks, never saw or attended the clinic. Therapist scheduled 7 live 0 min support session by telephone at weeks 1,2, 4, 6, 8, 10 and 12 London clinic-given appointments to use fearfighter on a stand alone computer in the clinic at weeks 1,2,4,6,8,10 and 12. Therapist gave support at start and end of each session, for a total of 10 min per session. | Computer | Fearfighter intervention (details of the intervention not available) | NR | NR | NR | NR | NR | NR | NR | Home internet users Mean use= 16 times (±11), over 66 days (±25) London clinic Mean total of 237 min (±57) at the clinic | NR | Internet users generally satisfied and felt comfortable using the system (Further info available on request) 3 pts said they would prefer face to face guided self help to internet guided self help. | NR | Week 0 vs. Week 12 vs. Week 16 vs. Change vs. Effect size FQ Global phobia (0–8), Mean (SD) Home internet: 6.0 (±1.2) vs. 3.4 (±1.3) vs. 2.8 (±1.7) vs. 53 (p<0.001) vs. 1.5 London clinic: 5.4 (±2) vs. 3.2 (±1.8) vs. 3.2 (±1.6) vs. 41 (p<0.001) vs. 0.4 FQ total phobia (0–120), Mean (SD) Home internet: 46 (±27) vs. 32 (±24) vs. 35 (±23) vs. 24 (p< 0.001) vs. 0.4 London clinic: 49 (±27) vs. 32 (±23) vs. 33 (±27) vs. 33 (p<0.001) vs. 0.6 FQ depression (0–8) Home internet: 4.1 (±1.9) vs. 3.2 (±4) vs. 2 (±1.5) vs. 51 (p<0.05) vs. 0.6 London clinic: 4.3 (±2.4) vs. 4.3 (±7.1) vs. 2.9 (±2.1) vs. 33 (p<0.05) vs. 0.8 FQ Anxiety/depression (0–48) Home internet: 19.4 (±6.6) vs. 19 (±4.8) vs. 7 (±4.1) vs. 64 (p<0.001) vs. 1.8 London clinic: 25.8 (±13.3) vs. 14.1 (±10) vs. 17.5 (±13.3) vs. 32 (p<0.001) vs. 0.6 WSA total (0–40) Home internet: 19.1 (±10) vs. 12 (±7.3) vs. 11 (±10) vs. 42 (p<0.001) vs. 0.8 London clinic: 17 (±10) vs. 12 (±10.7) vs. 10 (±10) vs. 41 (p<0.05) vs. 0.8 | NR | NR | NR | 266 referred to clinic 56 met criteria for treatment with fearfighter 154 met criteria for clinic's other computer aided self help systems for depression, general anxiety and obsessive compulsive disorder 56 more were unsuitable for computer aided treatment Out of 56 pts in the fearfighter grp 13 refused self help 43 began using intervention, 16 dropped out before completion of treatment (all in the clinic grp) | NR | Internet users had slightly more therapist support than stand alone computer users 113 min (±28.1) vs. 99 min (±11.4), t= -1.42, p=0.16
Kim | 2006a | Outpatient diabetes clinic | University hospital | Homes | RCT | N = 73 Grp 1: 28 Grp 2: 22 Grp 3: 23 | NR | 3 mos | *Age 20 years and older *FBS less than 240 mg/dL and/or *Diabetes mellitus history less than 20 years *No chronic complications of severe retinopathy, nephropathy, or neuropathy *No evidence of heart disease, musculoskeletal disorders, or other disabling diseases that could restrict physical activity *No insulin administration | NR | NR | NR | DM | NR | N = 53.4% | Mean: 55 | Korean | NR | NR | NR | NR | NR | Korean | Korean | NR | NR | WB= Web-based intervention, included interactive and animated features, stage-based personalized sections on goal setting, activity planning, determining target heart rates, and psychological and physical readiness questionnaires. Assist sequential movement through relevant stage-based information. | Group 1: WB (web-based intervention group) Group 2: PM (print material intervention group) Group 2: UC (usual care group) | Web-based intervention | Education, assessment, advice sending | Health care providers had to be fully trained for the constructs and meaning of TTM and use of the web-based intervention | NR | NR | FBS: Grp 1 and Grp 2 both decreased significantly, however did not differ significantly Grp 1 and Grp 2 decreased significantly more than Gp 3 (P<0.05, both) HbA1C: Grp 1 and Grp 2 both decreased significantly, however did not differ significantly Grp 1 and Grp 2 decreased significantly more than Gp 3 (P<0.01 and P<0.05, respectively) | NR | NR | NR | NR | NR | 82.9% of Grp 1 reported satisfaction with the intervention | NR | NR | NR | Physical Activity: Both Grp 1 and Grp 2 increased significantly (P<0.001), however the 2 groups did not differ significantly Grp 1 and Grp 2 increased significantly more than Grp 3 (P<0.01 and P<0.001, respectively) | NR | NR | NR | NR
Kim | 2007 | NR | Endocrinology outpatient department of tertiary care hospital in South Korea | Homes | Cohort | N=60 Control group: 30 Intervention group: 30 | Jan 2003 to Aug 2004 | 12 weeks | *Pts should be able to perform blood glucose testing and self injection of medication *Access the website *Have their own cellular phone | Clinical history of an important illness, renal insufficiency with a creatinine level > 0.08 mmol/l, or had been using insulin pumps. | NR | NR | DIABETES | NR | CG: 42.3% IG: 44% | CG: 47.5 (9.1) IG: 46.8 (8.8) | NR | NR | NR | NR | BMI (kg/m2), CG vs. IG 23.4 (±2.5) vs. 24.5 (±2.9) Diabetes duration (yrs) CG : IG: 8 (±4.9) : 5.2 (±5.9) Treatment method, CG : IG Insulin: 8 (±30.8) : 8 (±32) OHA: 18 (±69.2) : 17 (±68.0) Glucosylated hemoglobin (%): 7.59 (±1.09) : 8.09 (±1.72) Fasting plasma glucose (mmol/l): 7.9 (±1.3) vs. 8.4 (±1.4) 2HPMG (mmol/l): 12.9 (±4.3) vs. 14.2 (±4.5) | NR | NR | NR | NR | Nurse short messaging service | To investigate the effectiveness of an educational intervention that used both cellular phone and the internet to provide SMS relating to plasma glucose levels. | CG: pts met the endocrinologist once or twice during the study period and were given recommendations about medication, medication dosage and lifestyle modification by the specialist IG: pts logged in website and sent their self monitored blood glucose levels and drug information, including the kinds and dosages of insulin and oral anti diabetic medications; data transported to the internet server system and automatically displayed on individual electronic chart in the homepage and pts able to see the recommendations as well as data on the website (After integrating the information, the researcher sent optimal recommendations back to each pt, weekly, by a SMS by a cellular phone or wired internet) | Cellular phone, computer | Data collection, recommendations by SMS | NR | Pt trained on entering data on the website for 30 mins by a researcher | Glycosylated hemoglobin (%); CG vs. IG Baseline: 7.59 (±1.09) vs. 8.09 (±1.72) 3 months: 7.66 (±0.91) vs. 6.94 (±1.04) Group: 0.22 (±0.644) Time: 7.46 (±0.008) Group X Time: 8.35 (±0.005) Fasting plasma glucose (mmol/l) Baseline: 7.9 (±1.3) vs. 8.4 (±1.4) 3 months: 8.2 (±2.3) vs. 8.0 (±1.9) Group: 0.07 (±0.787) Time: 0.40 (±0.532) Group X Time: 3.03 (±0.088) 2 HPMG (mmol/l) Baseline: 12.9 (±4.3) vs. 14.2 (±4.5) 3 months: 13.7 (±4.2) vs. 9.5 (±4.3) Group: 2.34 (±0.135) Time: 3.34 (±0.076) Group X Time: 8.23 (±0.007) | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | IG: 5 subjects did not record their glucose levels for more than 4 weeks on the web site CG: 4 subjects were lost before completing post test, 1 moved to another city and three decided to opt out of the program before completing the post test | NR | NS
Kim | 2006b | Endocrinology outpatient department of tertiary care hospitcal located in an urban area | South Korea | Homes | Quasi-experimental, cohort, 1-group, pretest and posttest | N=45 | January 2003 to March 2004 | 12 weeks | *30 years of age or older *Access to internet in the home *Diagnosed diabetes *Able to perform perform blood glucose self-testing and self-injection of medication *Able to input data at the web site *Have their own cell phone | Not following the inclusion criteria, clinical history of heart failure, hepatic dysfunction, renal insufficiency with a creatinine level higher than 1.5 mg/dL, or had been using insulin pumps | NR | NR | DM | NR | 42% | 43.5 | NR | NR | NR | NR | Mean BMI: 24.3 Systolic BP: 117.2 mmHg Diastolic BP: 78.9 mmHg Duration of diabetes: 5.6 yrs HbA1c: 8.1% Fasting blood glucose: 164.9 mg/dL | NR | NR | Korean | NR | NR | Pts were asked to input blood glucose levels every day via internet or cell phone. Optimal recommendations were sent weekly to each pt via SMS | NR | Website and text messages | Data input and data receiver | NR | 30 minute instruction on how to input data at the website | NR | Glycosylated hemoglobin, % Pretest: 8.1 ± 2.1 Posttest: 7.0 ± 1.1 Difference: -1.1 ± 2.1 t: 2.89 P: 0.006 Adherence Diabetic diet, d/wk Pretest: 3.8 ± 2.8 Posttest: 3.0 ± 2.7 Difference: -0.8 ± 1.8 t: 1.44 P: 0.182 30-minute physical exercise, d/wk Pretest: 2.5 ± 2.2 Posttest: 3.4 ± 2.2 Difference: 0.9 ± 2.0 t: 2.22 P: 0.036 Diabetic medication taking, d/wk Pretest: 4.8 ± 2.6 Posttest: 5.9 ± 1.9 Difference: 1.1 ± 1.9 t: 2.36 P: 0.32 Foot care, d/wk Pretest: 4.9 ± 3.0 Posttest: 6.0 ± 2.3 Difference: 1.1 ± 2.2 t: 2.33 P: 0.30 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | 12 pts did not record their glucose levels for more than 4 weeks on the website | NR | Secondary Outcomes at 12 mos for all pts completing f/u in the electronic communications and home blood pressure monitoring trial; Mean (SD) # of antihypertensive medication classes Missing Data: 0 Baseline: 1.64 (±0.85) UC: 1.69 (±0.91) IVR: 1.94 (±0.91) IVR + PC: 2.16 (±0.93) Differences between IVR Groups, Mean Difference or RR (95% CI) UC vs IVR: 0.3 (0.1 to 0.4) UC vs IVR + PC: 0.5 (0.3 to 0.6) IVR vs IVR + PC: 0.2 (0.1 to 0.4) Aspirin use, No. (%) Missing Data: 38 Baseline: 338 (±48.8) UC: 124 (±53.0) IVR: 131 (±56.0) IVR + PC: 149 (±66.5) Differences between IVR Groups, Mean Difference or RR (95% CI) UC vs IVR: 1.1 (0.9 to 1.2) UC vs IVR + PC: 1.3 (1.1 to 1.5) IVR vs IVR + PC: 1.2 (1.0 to 1.4) Body mass index Missing Data: 34 Baseline: 32.3 (±6.5) UC: 32.5 (±6.5) IVR: 32.5 (±7.0) IVR + PC: 31.6 (±6.2) Differences between IVR Groups, Mean Difference or RR (95% CI) UC vs IVR: 0 (-1.1 to 1.2) UC vs IVR + PC: -0.9 (-2.1 to 0.3) IVR vs IVR + PC: -0.9 (-2.1 to 0.3) Active, No. (%) Missing Data: 49 Baseline: 464 (+68.1) UC: 158 (±68.4) IVR: 173 (±73.9) IVR + PC: 155 (±71.8) Differences between IVR Groups, Mean Difference or RR (95% CI) UC vs IVR: 1.1 (1.0 to 1.2) UC vs IVR + PC: 1.0 (0.9 to 1.2) IVR vs IVR + PC: 1.0 (0.9 to 1.1)
Kosma | 2005 | Rehabilitation centers, hospitals, colleges, and disability newsletters | NR | Homes | Pilot Study; RCT | N=75 | NR | 4 weeks | *Female age: 18–54 *Male age: 18–44 *Inclusion criteria based on health status, stages of change level, age range, disability type, internet access, but is NR what specifically was used to include/exclude pts | Unclear | NR | NR | NR | Physical Disability Amputation: 5.3% Cerebral palsy: 18.7% Muscular dystrophy: 4% Spinal Cord injury: 33.3% Multiple Sclerosis: 21.3% Cerebral Palsy: 18.7% Other: 17.3% | 28% | 38.73 yrs (+8.86) | Caucasian: 89.3% African-Americans: 5.3% | NR | College Grad: 49.3% Graduate degree: 29.3% HS grad: 4% Some college: 17.3% | NR | Stages of Change Precontemplation: 10.7% Contemplation: 37.3% Preparation: 33.3% Action: 9.3% Maintenance: 9.3% | NR | NR | NR | NR | NR | Web-based physical activity motivational program with and without discussion, weekly motivational messages | IVR (n=46): 4 week web-based physical activity motivational program with a different lesson plan for each link CG (n=29): no intervention | Website and emails | Motivational messages, discussion | NR | NR | NR | Posttest CG: more active 9.3 MET hrs/day IVR: 6.1 MET hrs/day | NR | NR | NR | NR | 75% found the program appropriate for national distribution among adults with physical disabilities, easy to use scored 4.5 out of a 5 pt scale | Out of a 5 pt scale (5 highest, 1 lowest) Helpfulness: 3.4 (±1.4) Ability to change physical activity: 3.4 (±1.4) Ability to maintain physical activity: 3.3 (±1.2) | NR | NR | Stages of change Pretest, n Preconemplation: 8 Conemplation: 28 Preparation: 25 Action: 7 Maintenance: 7 Stages of change Posttest, n Precontemplation: 7 Conemplation: 21 Preparation: 22 Action: 13 Maintenance: 12 | NR | NR | NR | NR | NR
Kressig | 2002 | Community dwellers | VA rehabilitation center and a local senior center | Unclear | Cohort | N= 34 | NR | NR | *60 yrs of age and older without medical contraindication for exercise *Intact manual dexterity (ability to dial a phone number) *Intact near vision (ability to read a newspaper) *System included prescreening procedures to ensure pts are at minimal risk for falls and demonstrate normal cognitive function and normal mood | NR | YES: 60 yrs and older | NR | NR | NR | 50% | Mean: 7.04 (±6.9) Range: 60–87 | NR | $10,000 to $39,000: 11 $40,000 or higher: 17 Did not want to say: 6 | Some college education or more: 33 | NR | No or very little computer experience:15 Cognitive function as measured by OMCT ranged from 0 to 10 with 30 pts (out of 32) scoring between 0 and 2 | NR | NR | NR | NR | Exercise expert system | System is a computerized health promotion tool whose ease of use and acceptability of the exercise recommendations were rated by pts. Time and assistance requirements and ability to successfully interface with the software were also evaluated. | Exercise expert system: software generates individualized exercise prescriptions for older healthy individuals based on responses given by clients and their practitioners to three different questionnaires, questionnaires pertain to medical history, mood, functional status, mental status, and specific preferences known to influence exercise behavior and maximize subsequent adherence. | Computer | Tailored exercise prescriptions | NR | System training manual: illustrated training manual with elementary mouse training and general instructions for interaction with the system. Pts were seated in front of computer and left alone with the manuals until they were ready to start the computerized questionnaire. Pts encouraged to ask questions after reviewing the manual. | NR | NR | NR | NR | NR | Mean (SD), Min to Max in minutes Training time: 3.76 (±1.50), 1–7 Completion time: 32.58 (±15.57), 12–79 | Mean (SD), min-max Ease of use score (0–5) 4.58 (±0.66), 3–5 Requests for assistance Mouse related: 0.67 (±1.16), 0–5 Non mouse related: 2.36 (±1.90), 0–8 | Mean (SD), min- max Prescription acceptability score (6–24) 21.45 (±2.24), 15–24 | NR | NR | NR | NR | NR | 33 pts completed the protocol, 1 male pt unable to complete because of fatigue | NR | Pearson correlation (p values) for objective performance measures Measures; Total time vs. total assistance vs. mouse related vs. non mouse related Age: 0.314 (0.750) vs. 0.532 (0.001) vs. 0.338 (0.054) vs. 0.491 (0.004) Computer experience: - 0.456 (0.008) vs. - 0.389 (0.025) vs. - 0.303 (0.086) vs. - 0.325 (0.065) Education: 0.049 (0.785) vs. - 0.116 (0.521) vs. - 0.227 (0.203) vs. - 0.013 (0.944) OMCT score: 0.218 (0.222) vs. 0.081 (0.654) vs. -0.089 (0.622) vs. 0.161 (0.371) Income: - 0.248 (0.164) vs. - 0.204 (0.256) vs. - 0.139 (0.442) vs. - 0.182 (0.310) Ease of use score: - 0.481 (0.005) vs. - 0.427 (0.013) vs. - 0.311 (0.079) vs. - 0.370 (0.034) Prescription acceptability score: - 0.008 (0.967) vs. - 0.057 (0.754) vs. 0.1 (0.579) vs. - 0.136 (0.451) Pearson correlation (p values) for subjective performance measures subjective ratings ; ease of use vs. prescription acceptability Age: - 0.493 (0.004) vs. 0.004 (0.981) Computer experience: 0.287 (0.105) vs. - 0.182 (0.310) Education: - 0.254 (0.154) vs. - 0.218 (0.223) OMCT score: 0.057 (0.753) vs. 0.272 (0.126) Income: 0.017 (0.927) vs. 0.225 (0.208)
Kwon | 2004 | Outpatient clinic | Kangnam St. Mary's Hospital Diabetes Center | Homes | RCT | N = 110 Grp 1: 55 Grp 2: 55 | May–August 2001 | 3 mos | *Type 2 diabetes for ≥1 year *Internet access *≥30 years old | Significant diseases that were likely to affect the outcome and compliance of this study Any who had participated in other programs that provided any information or education for diabetes management | NR | NR | TYPE 2 DM | NR | Grp 1: 58% Grp 2: 64% | Mean Gp 1: 54 Gp 2: 53 | Korean | NR | NR | NR | NR | NR | Korean | Korean | NR | Web-based diabetes management system | NR | Group 1: Intervention group Group 2: Control group | NR | NR | NR | NR | NR | At 12 week follow-up HbA1C levels for Grp 1 decreased from 7.59 at baseline to 6.94%, (P<0.001) and decreased significantly more at follow-up than Grp 2 (P<0.05) HDL for Grp 2 changed from 47.9 to 50.6 mg/dl (P<0.05) No other significant changes | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | N = 9 Grp1: 2 for not following the study protocol, 2 for lost to follow-up Grp 2: 5 for lost to follow-up | NR | NR
Labiris | 2004 | Internet | Urban areas of USA, EU, Canada, and Australia | Homes | Cohort | N=1,234 Counseling given to 1,021 | 8 yrs | NR | NR | Need for physical examination and insufficient provision of medical data were the main reasons for failure to answer all requests | NR | YES | YES: Orthopedic related illnesses | NR | 60.50% | Men: 43 (18–77) Women: 55 (32–75) | NR | NR | NR | YES: urban areas of EU, USA, Canada, and Australia | NR | NR | NR | NR | NR | NR | Internet-based counseling: patients would send e-mails to panel of physicians and orthopedic surgeons, and GPs, and these professionals would respond | Number of Requests Systemic diseases: 764 Pediatric orthopedics: 154 Sports Injuries: 143 Hand: 81 Fracture complications: 64 Misc: 28 | E-mail | To provide online counseling to pts | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
LaFramboise | 2003 | NR | NR | Homes | RCT | N= 90 Telephonic grp: 26 Home visit: 23 Health buddy: 21 Home visit/health buddy: 20 | NR | 2 months | *Inclusion criteria were oriented to person, place and time *No visual impairment *Ability to speak and read English *Having an active phone service. | NR | NR | NR | CHF | NR | Telephonic: 16.7% Home visit: 7.8% Health buddy: 13.3% Home visit/health buddy: 12.2% Total: 50.0% | Mean (Range) Telephonic: 67.6 (41–86) Home visit: 73.4 (53–85) Health buddy: 66.5 (39–91) Home visit/health buddy: 74.4 (56–90) Total: 70.3 (39–91) | Telephonic vs. Home visit vs. Health buddy vs. Home visit+health buddy vs. Total Caucasian: 25.6 % vs. 20.0% vs. 21.1% vs. 17.8% vs. 83.3% African American: 3.3% vs. 4.4% v 2.2% vs. 3.3% vs. 13.3% Other: 0.0% vs. 1.1% vs. 0.0% vs. 1.1% vs. 2.2% | Mean (Range) Telephonic: $16,646 (5837–32,000) Home visit: $ 15,179 (5584–32,000) Health buddy: $ 20,101 (5700–50000) Home visit+health buddy: $ 21,680 (5800–65000) Total: $ 18,380 (5584–65,000) | Mean (Range) Telephonic vs. Home visit vs. Health buddy vs. Home visit+health buddy vs. Total 11.4 (7–14) vs. 10.6 (3–16) vs. 11.9 (6–18) vs. 11.9 (8–16) vs. 11.4 (3–18) | NR | Living arrangement (%) Telephonic vs. Home visit vs. Health buddy vs. Home visit+health buddy vs. Total Alone: 5.6 vs. 10 vs. 8.9 vs. 8.9 vs. 33.3 With spouse/significant other: 17.8 vs. 8.9 vs. 12.2 vs. 11.1 vs. 50 With other relative: 5.6 vs. 5.6 vs. 2.2 vs. 2.2 vs. 15.6 In home assistant or assisted living: 0 vs. 1.1 vs. 0 vs. 0 vs. 1.1 | NR | NR | NR | NR | Health buddy | Simple, user friendly, readily visible, desktop telehealth communication device with daily interventions with recovery assessment, strategies to manage problems, education and positive reinforcement | Telephonic: Baseline focused physical assessment; HF disease management program (nurse provides assessment and education thru 5 weekly phone calls); HFP patient education notebook, non emergency phone number provided to call with questions; 2-month focused physical assessment Home visit: Everything same as above except that pts received 5 weekly home visits instead of phone calls Health buddy: everything similar to telephonic grp except Assessment and educational components of the HFP provided daily through Health buddy for up to 6 months with phone calls to pts as needed for follow up of high risk responses Home visits+health buddy: similar to telephonic grp except HFP provided through 5 weekly home visits plus health buffy for up to 6 months with phone calls to pts as needed for follow up of high risk responses. | Computer | Education, communication, response to questions | NR | NR | NR | Functional status, Mean (SD) Telephonic vs. Home visit vs. Health buddy vs. Home visit+health buddy Baseline: 574.3 (373.6) vs. 510.3 (266.6) vs. 682.4 (465.26) vs. 599.2 (281.25) 2 month: 633.16 (434.13) vs. 604.44 (319.9) vs. 723.4 (462.8) vs. 637.3 (264.2) F (p)= 8.4 (0.005) Role-physical, mean (SD) Telephonic vs. Home visit vs. Health buddy vs. Home visit+health buddy Baseline: 52.9 (44.9) vs. 38(44.5) vs. 31 (36.1) vs. 41.7(40.6) 2 mo: 62.5 (44.9) vs. 58.6 (44.3) vs. 58.3 (48.3) vs. 59.6 (44.7) F (p)= 12.7 (0.001) Bodily pain, mean (SD) Telephonic vs. Home visit vs. Health buddy vs. Home visit+health buddy Baseline: 53.7 (26.7) vs. 59.7 (29.8) vs. 56.7 (32.8) vs. 57 (30.6) 2 mo: 57.3 (24.8) vs. 68 (29.4) vs. 63.8(30.5) vs. 62.2 (22.8) F (p)= 4.2 (0.043) | NR | NR | NR | NR | NR | NR | NR | Mental status, Mean (SD) Telephonic vs. Home visit vs. Health buddy vs. Home visit+health buddy Baseline: 70.6 (21.8) vs. 73.9(21.1) vs. 76.2 (20.7) vs. 76.6 (17.4) 2 mo: 72.9(16.2) vs. 80(14.5) vs. 78.3 (20.8) vs. 83.2 (11.8) F (p)= 7.1 (0.009) Vitality Telephonic vs. Home visit vs. Health buddy vs. Home visit+health buddy Baseline: 39.4 (24) vs. 40.9(23.1) v 35 (22) vs. 37(22.3) 2 mo: 39 (27) vs. 44.8(29) vs. 41.7(23.1) vs. 42.4 (19.5) F (p) = 7.6 (0.007) | NR | NR | NR | Out of 66 originally assigned to grp health buddy and grp health buddy/home visit 20 (30%) were not able to use health buddy and not eligible for inclusion or continuation Of these, 4 were not interested in being inconvenienced by the technology and 2 were weak or ill because of other conditions.6 lived in retirement homes and had no available outlet for health buddy's electrical cord. | NR | NR
Lahm | 1996 | Preschool special education class 2 classes in special schools, 4 classes in rural schools, 5 in medium-sized urban school districts, 7 in large metropolitan districts | Virginia | Classroom | Convenience Cohort | N=48 | 9 months | NR | *Ages 3–5 *Placement in a non-categorical preschool special education class | Not chosen by the teacher to participate in the study | NR | NR | NR | YES: physical/mental/emotional disability | 79.00% | Range: 3–5 | NR | NR | Preschool class | YES: classes recruited from urban and rural school districts | NR | NR | NR | NR | NR | NR | Computer programs designed to engage preschool age children with developmental, physical, or mental disabilities | IVR: 48 | Interactive multimedia software | Goal of the study was to identify software design features that enhance engagement of young children with disabilities with instructional software | 1 full-day workshop on a single-subject research and alternating treatments design | NR | NR | NR | NR | NR | NR | Twice a day for 5 minutes for a maximum of 15 days | NR | NR | NR | NR | NR | NR | NR | 19 students had incomplete data | NR | NR
Lee | 2007 | Metabolism Center | NR | Homes | RCT | N = 274 Grp 1: 134 Grp 2: 140 | September 2003–May 2004 | 6 mos | *No severe complications that would affect the patients' ability to follow physician's orders *Normal level of consciousness Ability to read and communicate with spoken language *Have internet access | Invalid test results on one of the laboratory tests | YES | NR | TYPE 2 DM | NR | Grp 1: 57% Grp 2: 46% | Range [underlined: <29] Grp 1: 7.4% Grp 2: 2.1% [underlined: 30–39] Grp 1: 7.5% Grp 2: 2.1% [underlined: 40–49] Grp 1: 15.7% Grp 2: 9.3% [underlined: 50–59] Grp 1: 34.2% Grp 2: 29.4% [underlined: 60–69] Grp 1: 18% Grp 2: 27.9% [underlined: 70–79] Grp 1: 14.2% Grp 2: 26.4% [underlined: >80] Grp 1: 3% Grp 2: 2.8% | NR | NR | Illiterate Grp 1: 9.8% Grp 2: 12.1% Elementary school/Junior high school Grp 1: 32% Grp 2: 27.2% High School Grp 1: 15.7% Grp 2: 20% College or University Grp 1: 38.8% Grp 2: 38.6% Masters or PhD Grp 1: 3.7% Grp 2: 2.1% | NR | NR | NR | NR | NR | NR | POEM | Web-based system for managing patients' care of their diabetes | Group 1: Intervention group that used POEM Group 2: Control group | Web-based intervention | Education, medical data retrieval, reminders | NR | Intervention group received training on accessing the internet, using the POEM system, and reading their cell phone messages | NR | [underlined: Fasting blood glucose (mg/dl)] Grp 1: 125.14 to 108.82 vs. Grp 2: 137.69 to 125.99 P=0.001 [underlined: HbA1C (%)] Grp 1: 8.56 to 6.74 vs. Grp 2: 8.90 to 7.42 P=0.001 [underlined: Total cholesterol level (mg/dl)] Grp 1: 180.01 to 160.99 vs. Grp 2: 189.56 to 174.60 P=0.012 | NR | NR | NR | Education Differences Those in the education category of “College or University” logged into the POEM system more often than those in the education category of “Illiterate” or “Elementary school/Junior high school” (P=0.007 and P=0.012, respectively) Age Differences Those in the age category of <29 years logged into the POEM system more often than those in the age category of 50–59, 60–69, and 70–79 (P=0.011, P=0.000, P=0.000, respectively) Those in the age category of 40–49 years logged into the POEM system more often than those in the age category of 60–69 and 70–79 (P=0.012 and P=0.040, respectively) | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Leu | 2005 | University of Washington Physician's network clinics. (no other details given) | 20 Primary care providers and 2 endocrinologist clinics | Homes | RCT | N=50 CG: 25 Exp Grp: 25 | Enrollment occurred from November 6, 2001 through July 8, 2002, The last patient de-enrolled on December 20, 2002 | 3–6 months | *Pts with HbA1c values between 8.0%–9.4% at the time of recruitment with either Type 1 or Type 2 Diabetes. | NR | NR | NR | DIABETES | NR | NR | Mean: 51 | Predominantly Caucasian | NR | NR | Unclear | Type 2 Diabetes: 37 pts Type 1 Diabetes: 13 Pts with Type 1 Diabetes were more likely to participate in the study;1 in 4 participated Pts with Type 1 Diabetes were younger (average age is 46 yrs) The rate of participation between pts referred by a PCP or an Endocrinologist was the same 19 pts had Hb1Ac checked within 3 months prior to the study enrollment | NR | NR | NR | NR | NR | Wireless two way pager based automated messaging system offering appointment reminders, medication reminders, blood glucose testing reminders, exercise reinforcement, dietary reinforcement, meal time reinforcement, and lab result reporting were offered along with custom reminders of time and birthdays, messages sent to pts via email, pt information stored in the diabetes registry. Responses processed by a constantly running program that forwarded unexpected responses to investigator | Group 1 (Pager): all of the above, training on the use of pager provider, investigator could be reached anytime. Pts had contact numbers and also the number of the UWPN clinic and instructions to dial 911 for emergencies. Group 2 (No pager): Pts in pager group could interact with the health care team by sending and receiving paper messages Pts in control group could page the investigator | Pager | Send and receive short text messages, Pt could respond to a message with a canned response or by typing in a small rudimentary keyboard. | NR | Pts in the pager group received instructions on how to use the pager. | NR | HbA1c No pager (n= 19) vs. pager (n=18) Prior to enrollment: 8.5% vs. 8.5% Preliminary interview: 8.2% vs. 8.3% Exit interview: 7.9% vs. 8.2% Difference (Mean +/- SD)= - 0.3+/- 1.12% vs. - 0.13 +/-0.93% Blood pressure (% hypertensive) No pager (n= 19) vs. pager (n=18) Preliminary interview 68% (17/25) vs. 64% (16/25) Preliminary (stayed enrolled) 71%(15/21) vs. 62%(13/21) Exit interview 76%(16/21) vs. 38% (8/21) | NR | NR | NR | Messaging system sent 21,764 messages out of which 12,025 sent to the patient. 1,676 replies, out of which 114 were non-canned 2 pts utilized the system by replying to as many messages as they can i.e. 770 of 884 (87%) and 708 of 830 (85%). System statistics in detail given in tabular form, not listed here. | NR | Attitudes towards technology: pager (post) Messages Annoying to comforting: 7.7 Unhelpful to helpful: 7.0 Inconvenient to convenient: 8.5 Not useful to useful: 7.8 Patient felt not cared for to cared for by the health care team: 8.5 | Attitude towards the health care team Pager vs. No Pager Overall satisfaction with diabetes related care Pre: 8.5 vs. 8.5 ; Post: 8.8 vs. 7.9 Clear treatment plan Pre: 8.6 vs. 7.8; Post: 8.8 vs. 8.3 Possible side effects of medications are clear Pre: 8.2 vs. 8.5; Post: 8.5 vs. 7.8 Questions concerning diabetes answered Pre: 7.8 vs. 8.4; Post: 8.5 vs. 8.1 | NR | Attitude towards diabetes Pager vs. No pager Plan for hypoglycemia Pre: 8.4 vs. 7.3; Post: 8.3 vs. 7.8 Health: poor to excellent Pre: 6.2 vs. 6.5; Post: 6.8 vs. 7.0 Diabetes.- unmanageable to manageable Pre: 6.2 vs. 6.4; Post: 7.2 vs. 7.0 Glucose monitoring Unimportant to important Pre: 8.2 vs. 8.3; Post: 8.0 vs. 8.3 Not done to regularly Pre: 7.8 vs. 6.8; Post: 8.0 to 7.2 Difficult to easy Pre: 8.4 vs. 7.3; Post:8.6 vs. 7.6 Treatment plan Realistic to Unrealistic Pre: 7.5 vs. 8.2; Post: 8.1 vs. 8.1 Health care better at end of study: No to yes No pager (post) vs. pager(post) 5.8 vs. 7.2 | NR | Poor to good family support: Pager group (post)= 8.0 | Pager group: 3 withdrew (1 did not use pager, 1 lost the pager, 1 stopped because he felt he received too many pages) and 1 patient passed away from complications of stroke. Experimental group: 3 withdrew and 1 was lost to follow up. | NR | The different message types requested are given, not listed here There is also a table with the message system statistics Messages were annoying: 44% (8/18) Messages were from my physician: 13%(2/15) Messages were not applicable: 12% (2/17) Pager worked (no problems): 71% (15/21) Enjoyed using the pager: 79% (15/19) Want to continue program now that study is over: 68% (13/19)
Levetan | 2002 | American Diabetes Association program 3mos prior to enrollment | Penn Medical Laboratory, Washington D.C. | Homes | RCT | N=150 | 6 mos | NR | *Completing an ADA recognized diabetes education program during the 3mos period before study enrollment | *History of renal insufficiency with Creatinine level > 1.5mg/d *Women who were pregnant at the time or planning a pregnancy during the study period *Pts using insulin pumps *Illiterate pts *Pts receiving blood transfusion within past 30 days *Pts with underlying illness affecting chances of survival during study period | NR | NR | DIABETES | NR | CG: 30 IVR: 35 p=0.71 | CG: 60 IVR: 57 p=0.25 | African American CG: 83 IVR: 89 p=0.32 | NR | Education (% no college) CG: 44 IVR: 47 p=0.62 | NR | Systolic BP (mmHg) CG: 143 IVR: 142 p=0.85 Diastolic BP (mmHg) CG: 83 IVR: 83 p=0.80 Duration of diabetes (years) CG: 3 IVR: 5.5 p=0.10 HDL (mg/dl) CG: 41 IVR: 42 p=0.57 LDL (mg/dl) CG: 116 IVR: 115 p=0.98 HbA1c (%) CG: 8.39 (±2.03) IVR: 8.85 (±2.48) p=0.25 Microalbuminuria (% with 30–300 micrograms) CG: 61 IVR: 58 p=0.72 | NR | NR | NR | NR | DiaLOG (Diabetes List of Goals) | Computer-generated customized report presented as an 11″×17″ laminated color poster with magnets, with a bulleted list of personalized goals and recommended steps for achieving the goals | IVR: 75 Received computer-generated poster as well as 1 phone call from a health educator discussing the poster and the plan Pts also received a color report that was designed for the pts' medical record; in addition to graphic display of HbA1c, information included pts' BP, lipid, and microalbumin status, and date for pts' next dilated retinal examination | Computer-generated report (poster) | Education, goal setting, encouragement, knowledge | NR | NR | NR | Changes from baseline at follow-up Weight (lb) CG: +1.0 IVR: +1.54 Systolic BP (mmHg) CG: -4 IVR: -4 Diastolic BP (mmHg) CG: -5 IVR: -4 HDL (mg/dl) CG: +3 IVR: +3 LDL CG: -7 IVR: -5 Changes in HbA1c from Baseline Baseline (%) CG: 8.39 (±2.03) IVR: 8.85 (±2.48) End of Study (%) CG: 7.79 (±1.91) IVR: 7.78 (±2.22) Change from Baseline (%) CG: -0.6 (p>0.05) IVR: -1.08 (p=0.013) | NR | NR | Pt Characteristics at Baseline Heard of an “A-One-C” test (%) CG: 52 IVR: 42 p=0.47 Changes from baseline at Follow-up Heard of a “A-One-C” test (%) CG: -5.1 IVR: +14.3 | NR | NR | NR | NR | NR | NR | NR | NR | CG 1 death 3 pts developed debilitating syndromes and dropped 7 pts declined F/u IVR 1 death 2 lost laboratory specimens 7 pts declined F/u 1 developed debilitating illness Final # of pts: 128 | NR | NR
Lieberman | 2003 | WWW | NA | WWW | Cross-sectional cohort study | N = 1455 Non-abuse: 248 Alc. Abuse: 1207 | March 2001 – April 2003 | NA | *Internet connection *Registration with alcoholcheckup.com *Informed consent | Unable to provide consent or “understand text” (NR how this was measured) | NR | NR | ALCOHOL DEPENDENCE/USE | NR | Non-abuse: 54.5% Alc. Abuse: 52.8% | Mean Non-abuse: 35.5 Alc. Abuse: 34.8 | NR | NR | NR | NR | Mean drinks/week: Non-abuse: 9.6 Alc abuse: 36.4 (p<.001); Age first drink: Non-abuse: 17.2 Alc abuse: 16 (p<.001); | NR | NR | NR | NR | alcoholscheckup.com | Information tailored to data entered for 5 questionnaires; feedback scores on alcohol screening instruments, drinking compared to national averages | NR | WWW | Tailored information | NR | NR | NR | NR | NR | NR | Asked in information was new and “unexpected” to them Non-abuse: 8.3 Alc abuse 9.4: (p<.001); Correlation between unexpected information and helpfulness: 0.254 (p<.001) | NR | NR | Perceived helpfulness overall: Non-abuse 8.9 Alc. Abuse 10.4 (p<.001); Among alc. Abusers, helpfulness of comparative drinking rates 3.8, SOCRATES screening tool feedback 3.3., AUDIT screening feedback 3.3; | NR | NR | Higher perceived helpfulness correlated with higher SOCATES scores (Pearson corr 0.295, p<.001), ability to recognize the problem (Pearson 0.3, p<.001), ambivalence about need to make a change (Pearson 0.3, p<.001), and having taken steps to change (Pearson 0.156, p<.001). | NR | NR | NR | NR | NR
Lorig | 2006 | Website postings | NR | Homes | RCT | N=958 CG: 501 IVR: 457 | 18 mos | 12 mos | *Age ≥18 yrs *Physician's diagnosis of heart disease, chronic lung disease or type 2 diabetes *Access to a computer with internet and e-mail capabilities *Agree to 1–2 hours per week of log on time spread over at least 3 sessions/week for 6 weeks *Able to complete online questionnaire | Active treatment of cancer within 1 year; participated in the small-group Chronic Disease Self-Management Program | NR | NR | HEART DISEASE, HYPERTENSION, LUNG DIASEASE, DIABETES, ARTHRITIS | NR | Usual Care: 28.4%; Intervention: 28.8% | Mean (SD) Usual Care: 57.6 (±11.3) IVR: 57.4 (±10.5) | Caucasian Usual Care: 88.7%; Intervention: 87.3% | NR | Mean years (SD) CG: 15.8 (±3.16) IVR 15.4 (±3.00) | NR | NR | NR | NR | NR | NR | Internet-based Chronic Disease Self- Management Program (CDSMP) | Interactive web-based English-language instruction, web-based bulletin board discussion groups, and the book Living a Healthy Life with Chronic Conditions. Book contains all program content, as well discussions of the major types of chronic diseases, medication, and also has illustrations of suggested exercises. Each week for 6 weeks, participants are asked to log on at least 3 times for a total of 1 to 2 hours. Participation includes reading the week's content on web pages, posting an action plan on the bulletin board, checking in with a buddy via e-mail, and participating in any self-tests and activities. | Usual Care: received usual care (whatever care they had been receiving or chose to receive) Intervention group: usual care + the intervention above. Online moderator training: participation in workshop and then co-leading a workshop with a previously trained moderator. Moderators also have online manual that gives daily and weekly instructions as to moderator duties. | Website | Provide content on web pages, bulletin board, buddy email, self-tests and activities | Moderator Training; see intervention | NR | NR | NR | Mean (SD) Changes at 1 year: Physician Visits (during past 6 months): NS Emergency Visits (during past 6 months): Significant Usual Care: -0.144 (±1.82), Intervention:-0.00 (±1.06) (p=.030). no longer significant when 6 month data is included (p=0.141). Days in hospital (during past 6 months): NA | NR | NR | Average log in: 26.5 times (±22.8) Range: 0–177 | NR | NR | NR | Online/ usual care NS (trend p=.06) All subjects: baseline self-efficacy and increases at 6 months were associated with pain, fatigue, disability, illness intrusiveness, health distress, and global general health at 1 year (p< .001) and shortness of breath (p = .007) [underlined: M (SD) Changes at 1 year:] Self- efficacy: trend Usual Care: 0.200 (1.82) Intervention: 0.406 (1.98) (p=0.051) (effect size= .096) | [underlined: Mean (SD) Changes in Health Behaviors at 1 year:] Aerobic exercise: NS Usual Care: Significant Stretch/strength exercise: CG: 1.16 (±49.6) IVR: 11.9 (±60.4) (p=0.032) (effect size=0.308) Communication with physician: NS Practice stress management: NS | [underlined: M (SD) Changes in Health Indicators at 1 year] Health distress: Significant Usual Care: -0.193 (1.07) Intervention: -0.377 (1.11) (p=.013) (effect size=.160) Self-reported global health: NS Illness intrusiveness: NS Disability: NS Fatigue: Significant Usual Care: -0.358 (2.09) Intervention: -0.720 (2.14) (p=.011) (effect size= 0.151) Pain: Significant Usual Care: -0.047 (2.46) Intervention: -0.367 (2.72) (p= .008) (effect size= 0.106) Shortness of Breath: Usual Care: -0.216(2.40) Intervention: -0.537 (2.41) (p= .020) (effect size =0.097) | NR | UC: 15%, IVR: 22.5% Reasons NR | NR | Exploratory comparison of intervention group to original study of small group CDSMP. Health indicators, health behaviors, self-efficacy and health utilization are compared
Ma | 2006 | Diabetes Center, The Queen Elizabeth Hospital | Specialty outpatient clinic | Homes | Phase I: Use case study; Phase II: Cohort | Phase I: N = 14 Clinicians: 5 Patients: 11 Phase II: N = 17 Clinicians: 5 Patients: 12 | NR | Phase II: 3 months | Patients: *Diagnosed with diabetes in the past year in the hospital database *If no home internet, willing to use library Internet with assistance Providers: *Involved in diabetes management | NR | NR | NR | Phase I, Patients: 10 of 11 had TYPE 2 DIABETES, 1 had TYPE 1 DM Phase II, Patients: All TYPE 2 DM | NR | Phase I, Patients: 7 of 12 (58.3%) | Range Phase I, Patients: 38–62 Phase II, Patients: 35–65 | NR | NR | NR | NR | NR | NR | NR | NR | NR | Violet Technology | Diabetes Information Profile (DIP): info tailoring and priority algorithms; Quiz Service: quiz tailoring and priority algorithms; Agenda Service: agenda algorithms. | NR | Web portal | Patient profile data collection, information and quizzes tailored to profile (boolean filtering based on profile data) and priority weights (filtering using rules based on patient data, knowledge [level 1, 2, or 3], frequency of information review, and pt-reported information preferences); quizzes filtered based on patient data | Available | NR | NR | NA | NA | NA | NA | Patients, Phase II: Login times N=82, Individuals 2 to 15 (Median: 6) Use of InfoService all 12 patients: 82 out of 257 information items visited for 10 sec or greater; Use of QuizService, 5 of 12 pts: individuals did 5 to 110 quiz questions, (Mean: 61.8) Use of AgendaService, 1 of 12 pts | Phase II, patients N=9 (agree with the statements below): Easy to use: 7 Relevant to DM: 7 Tailored info meets needs: 6 Tailored info useful: 7 Tailored agenda useful: 7 Tailored agenda easy to follow: 6 Would recommend to others: 6 Would continue to use: 5 | Focus Group, patients: Experienced patients found the tailored information less useful because they knew it. Focus Group, professionals: less valuable for more experienced patients or those who have diabetes in control; should add HgA1c and weight tracking; provide summary feedback on quiz results. | NR | NR | NR | NR | NR | Phase 1: 1 of 12 | NR | Health professional feedback on program:
McClure | 2006 | 2 Health plans, Group Health Cooperative and Henry Ford Health System | Recruitment through the health plans (letters sent to smokers identified in EHR, and health plan newsletters) | WWW | Cohort study (recruitment study) | N = 1866 | Sept 2004 – July 2005 (recruitment) | NR | *GHC or HFHS member *Smoked 100 lifetime cigarettes *Current 10+ cig/day *Ready to quit next 30 days *Age 21–70 *Home/work access to Internet *E-mail account used 2×/week or more | Enrolled in smoking treatment program; medical contraindication to nicotine therapy | NR | NR | SMOKING | NR | N = 40.5% | Mean: 46.3 | Caucasian: 79.6% | NR | HS or less: 24.2% Vocational/tech: 11.9% Some College: 56.3% | NR | NR | Insured with participating health plan | NR | NR | NR | Project Quit | Recruitment study, not an intervention study; Project Quit is a tailored interactive tobacco treatment website plus nicotine patch therapy. | NR | Website | Web-based cognitive behavioral counseling, tailored interactive site | NR | NR | NR | NA | NA | NA | NA | 3256 visited project website 1866 enrolled in study Recruitment of site visitors: 69% from mailed letters, 21% from newsletter, 9% from other (provider referral, etc.) Estimated 1.6% and 2.5% of smokers enrolled in study (from health plan 1 and 2) | NR | NR | NA | NA | NA | NA | NA | NA | NA | NR
McDaniel | 2002 | Inner-city community health center | Indianapolis, Indiana | Clinic | Cohort | N=110 | NR | 1 week | *Female *Smokers *Attend inner-city community health center | NR | NR | NR | YES: SMOKING | NR | 0.00% | 41.5 (±12.4) Range: 18–71 | African-American: 23% Caucasian: 68% | NR | 35% did NOT have HS diploma | YES: attending inner-city community clinic | NR | NR | NR | NR | NR | A New Beginning | Computer program designed to give tailored smoking cessation messages in a format that would be relevant and acceptable to the users based upon the information entered by the pt | IVR: 100 | Computer program | Smoking cessation | NR | NR | NR | NR | NR | NR | NR | NR | Initially, non-applicable information would be presented to certain pt Avg. time to complete program: 13.9 minutes (Range 7.2–88.8 minutes) | Satisfaction Range of 14–70 Mean: 60.2 (±6.3) | NR | NR | Cut down on cigarettes: 52% Quit Smoking for 24 hrs: 15% Called a smoking cessation program: 6% Talked to a doctor about quitting: 15% Read information about quitting: 24% Discussed quitting with friends/family: 40% | NR | NR | N=10 | NR | NR
McKay | 2001 | Pts recruited by e-mail postings to diabetes specific UseNet groups, list serves, web sites and online community groups inviting them to participate in an internet based Physical activity(PA) program | NA | Homes | RCT | N= 78 IVR: 38 CG: 40 | 6 week recruitment period | 2 mos | *Diagnosis of Type 2 Diabetes *Age ≥ 40 years *Physical activity level below the current minimum recommendation by the American college of sports medicine (ACSM) and CDC (i.e. 30 mins of cumulative moderate intensity activity for 5 or more days/week) | NR | NR | NR | TYPE 2 DIABETES | NR | N = 47% | Mean: 52.3 | Caucasian: 82% | NR | Completed college: 50% | NR | Employed full time: 62% Taking insulin: 22% Diagnosed with diabetes for more than a year: 83% Had one or more co morbid condition: 75% | NR | NR | NR | NR | D-net active lives PA intervention | Multi-level, socio ecological model of diabetes self management and follow up support for behavioral change. The pts in the intervention group received goal setting and personalized feedback, identified and developed strategies to overcome barriers, received and could post messages to an on line personal coach and were involved in peer group support activities. | Control group; - received graphic feedback comparing baseline PA level to ACSM recommendations for moderate level PA; - received PA safety precautions.; - Access to information only website; Intervention group; - received graphic feedback comparing baseline PA level to ACSM recommendations for moderate level PA; - received 5 steps to action personalized PA plan that consisted of Benefits of PA (i.e. personal motivators), Goal setting, Activity exploration, Schedule of weekly activity, Barriers to PA and tips to overcome barriers.; - received support from personal coach that consisted of 5 tailored messages over 8 week period, correspondence as required by pts, referral to specific intervention web site areas and links, tips and reminders and schedule of weekly activity; - received ongoing support in the form of PA resources area, peer support groups and live chat, PA tracking and graphic feedback | Computer | Live chat, links to resources sites, messages, graphic feedback of PA levels, communications with personal coach | NR | NR | NR | Physical activity summary Moderate to vigorous exercise (min/day) Intervention vs. control Unadjusted; Baseline- 5.6 +/- 6.2 vs. 7.3 +/- 6.2 Unadjusted; follow up- 17.6 +/- 15.3 vs. 18.0 +/- 17.3 Log transformed; Baseline- 0.60 +/- 0.47 vs. 0.75 +/- 0.45 Log transformed; follow up- 1.03 +/- 0.57 vs. 1.12 +/- 0.42 Time---- F (1,64)= 29.59 (p<0.001) Group X time-------F (1,64) = 0.01 (p=0.938); n2= 0.000 Walking (min/day) Intervention vs. Control Unadjusted; baseline- 6.4 +/- 6.2 vs. 8.4 +/- 8.4 Unadjusted; follow up- 12.5 +/- 9.5 vs. 16.8 +/- 22.8 Log transformed; baseline- 0.68 +/- 0.45 vs. 0.78 +/- 0.46 Log transforms; follow up- 0.96 +/- 0.48 vs. 1.01 +/- 0.49 Time---------------- F (1,64)= 15.62, (p<0.001) Group X time--------F = 0.08 (p=0.781), n2=0.001 | NR | NR | NR | IVR vs. CG Web site activity analysis: 341 logons (1.1 logons/pt/week) vs. 105 logons (0.3 logons/pt/week) Total web pages viewed: 9962 vs. 1811 Pts average session duration: 3 mins vs. 11 mins Usage during first 2 weeks and last 2 weeks IVR: 204 logons (2.7/pt) and 40 logons (0.5/pt) CG: 77 logons (0.9/pt) and 7 logons (0.09/pt) IVR pts had 5938 page views (156.3/pt) within the behavior change focused active lives area and 310 page views (8.2/pt) within the diabetes specific information library area. IVR pts posted 80 messages (2.1/pt) to personal coach and 42 messages(1.1/pt) to peer support grp area | NR | Intervention vs. control Satisfaction: 4.9 (±1.4) vs. 3.7 (±1.7), Student's t value= 2.07, p=0.047 Program's relevance to pts needs: 5.1 (±1.2) vs. 4.1 (±1.2), t= 1.96, p=0.058 Ease of use, helpfulness of PA section- results did not differ significantly In the intervention group, 88% found personal coach helpful and 35% found peer support helpful | NR | Depressive symptoms (CES-D) Intervention vs. control Baseline; 16.9 +/- 11.6 vs. 17.6 +/- 10.4 Follow up; 14.9 +/- 12.5 vs. 19.9 +/- 14.2 Time------- F (1,64)= 0.06 (p=0.809) Group X time--------F(1,64) = 2.77 (p=0.101), n2=0.042 | NR | NR | NR | Out of 40 control pts, only 33 (82.5%) completed the post assessment survey Out of 38 intervention pts, only 35 (92.1%) completed the survey | NR | The total number of logons was used to determine the association between program use and the three outcome measures. ANOVA results given for the same, not listed here
McMahon | 2005 | Volunteer (solicited by mail and telephone) | VA Boston Healthcare System (4 hospital-based clinics and 10 community-based outpatient clinics) | Homes | RCT | N = 104 CG = 52 Intervention = 52 | October 2001–April 2003 | None | *HbA1C(>=) 9.0% *>18 yrs old *Ability to understand written and spoken English *“Willingness to use glucose-and blood pressure-monitoring devices” *Required to have a VA-based PCP *Access to a telephone | Lacking any/all of the stated criteria above | Mean age: 63(±)7 | NR | DIABETES | NR | CG: 100% Intervention: 99% | CG: 63(±) 7 Intervention: 64(±)7 | NR | NR | CG: College or Above: 67% High school graduate: 19% Some HS: 6% Below HS: 2% Intervention: College or above: 59% HS graduate: 22% Some HS: 12% Below HS: 6% | NR | NR | NR | NR | English | Believe that care management has been studied in diabetic patients, but that results have been mixed; believe that with increased use of internet in chronically ill, Internet may help improve QoL and quality of condition | MyCareTeam | Website displayed blood pressure and glucose monitoring outcomes in table and graphical form for patients and care management providers, contained web-enabled diabetes educational modules, provided links to other diabetes resource websites, and allowed secure chat/e-mail between patient and care provider. Information submitted was also reviewed by a certified diabetes educator and advanced practice nurse (made recommendations to patient and PCP). | CG: usual care with PCP Intervention: usual care + notebook computer, glucose meter, blood pressure monitor, and access to MyCareTeam website *Intervention group received computer training and support by the study staff (mean 2.3hrs per subject). Allowed to send e-mails to PCP and other experts | Internet, Telephone | Education and self-management skills, blood pressure monitoring was recommended at least 3 times weekly, and glucose monitoring was individualized to each patient | NR | Training time was dependent on comfort with computers/internet and devices provided | Additional education provided at regularly scheduled clinic visits | BEFORE STUDY: Mean A1C (%) CG: 9.9 (+-)0.8 Intervention: 10.0 (+-) 0.8 Blood Pressure (mmHg) Systolic, Diastolic: CG: 139(+-)20, 80(+-)7 Intervention: 141(+-)21, 81(+-)7 Lipids (mg/dl): LDL cholesterol CG: 97(+-)21 Intervention: 100(+-)35 HDL cholesterol CG: 40(+-)8 Intervention: 43(+-)14 Triglycerides CG: 204 (+-)140 Intervention: 178(+-)112 | Clinic visits at 0, 3, 6, 9, and 12 months for both groups Intervention Uploads: Medians: 1, 18, 31 Persistent User: Log-in every 3 months (n = 30) Intermittent User: Log-in > 3mos (n = 22) | NR | NR | NR | NR | NR | NR | NR | AFTER STUDY Overall: P < 0.001 Changes in A1C at 12mos CG: -1.2(±)1.4% Intervention: -1.6(±)1.4% P < 0.05 Persistent Users: -1.9(±)1.2 vs. Intermittent: -1.2(±)1.4 P = 0.051 CG: P <0.05 Persistent Uploaders: -2.1(±)1.1 vs. Lowest: -1.1(±)1.7 P < 0.05 Changes in BP at 12mos Hypertensive Patients Systolic BP CG (n = 35): -7(±)21 mmHg Intervention: (n = 37): -10(±)17 P < 0.01 Diastolic BP CG: -6(±)11 P = 0.058 v. baseline Intervention: -5(±)13 P = 0.053 v. baseline Hypertensive Patients at the end of the study CG: n = 37 Intervention: n = 28 Changes in Lipid Profiles LDL cholesterol CG: -5(±)11 mg/dl Intervention: -6(±)12 mg/dl HDL cholesterol CG: 1(±)6 mg/dl Intervention: 3(±)6 mg/dl P < 0.05 v. baseline Triglyceride Levels CG: -2(±)60 mg/dl Intervention: -38(u+)99 mg/dl P < 0.01 v. baseline | NR | NR | N = 20 CG: Lost to follow-up: 11 Withdrew Consent: 1 Intervention: Lost to follow-up: 7 Discontinued intervention: 1 | NR | Hypoglycemic episodes CG: 33 events in 11 participants (Median: 2/pt) Intervention: 46 events in 13 participants (Median: 3/pt)
McPherson | 2006 | Pediatric outpatient respiratory clinics | 3 United Kingdom hospitals | Homes | RCT | N=101 | 1 years | 6 months | *Had scheduled follow-up appointment at 1 of 3 clinics in the study period *Parental consent and child assent | Did not have a diagnosis of asthma, were not currently receiving treatment for asthma, or were assessed by parents or clinician to have significant learning or behavioral difficulties | NR | NR | YES: ASTHMA | NR | 54.00% | Median, Mode CG: 9, 7 IVR: 11, 8 | White CG: 86.3% IVR: 90% | NR | NR | NR | Mean duration of asthma CG: 6.64 (±3.12); 1–14 IVR: 6.91 (±3.64); 3mo to 13 | NR | NR | NR | NR | The Asthma Files | Interactive computer game with a secret-agent theme; as “secret agents” users are encouraged to explore all of the sections, finding out as much about self-management as possible by listening to voiceovers, completing quizzes, and engaging with interactive problem solving tasks | CG: 51 IVR: 50 | Computer game | To provide education about asthma to children | NR | NR | NR | 6 month Follow-Up Courses of Steroids, Mean IVR: -2.22, p=0.026 Days off school, Mean IVR: 2.1, p=0.034 | NR | NR | Mean change in Asthma Knowledge Assessment score CG: 1.55 (0.65–2.48) IVR: 3.97 (3.02–4.92) | 1–10 times | NR | 35 of 37 Felt that the game was a good way to learn about asthma, and the majority (31/37) believed that they had learned more about their asthma from using the package. | NR | NR | NR | NR | NR | 11 lost to follow-up | NR | NR
McTavish | 1994 | Inner city Chicago | Cook county hospital | Homes | Pilot study | N= 8 | Oct 1, 1993– Jan 15, 1994 | 15 weeks | *All African American women were stage 1 or stage 2 cancer pts | NR | No | Inner city Chicago African American women | BREAST CANCER | NR | All women | Range: 36–66 yrs 6 of the 8 women were 55 yrs or younger | African American | All women were on public assistance | Half never completed high school and 3 had prior computer experience | Urban (inner city) | Five had lumpectomies and two had mastectomies within the past year (5 had surgery within the past 6 months) Only 1 women had CHESS prior to deciding what surgery to have. | NR | NR | NR | NR | CHESS | CHESS: web based information, discussion group, ask an expert, and interactive services (tailored action plan, decision aides and health tracking) | Pilot study group with CHESS intervention | Computer | Forum, question and answers, library, expert communication, action plan. | NR | A CHESS staff member gave approx. 1 hour of instruction and orientation | NR | NR | NR | NR | NR | CHESS was used 886 times within the 15 wk period On avg, each woman used CHESS 7 times/ wk and was on the system for more than 1 hour/wk Use of social support components: 55% Information components: 41% Problem solving components: 4% Service: number of uses (minutes) Discussion groups: 442 (5046) Ask an expert: 227 (1487) Questions and Answers: 83 (617) Personal stories: 43 (504) Instant library: 48(341) Decisions and conflicts: 20 (208) Getting help/support: 18 (76) Action Plan: 5 (48) | Overall value of CHESS: 7.00 with three services rated below 7.00 AP (action plan) rated lowest at 6.50 Overall CHESS for ease of use: 5.80 and 6 of the services rated above 6.00 in ease of use AP rated lowest in terms of ease of use: 4.80 DG (disc. groups)was the most used despite the lower ease of use core CHESS is extremely user friendly and lack of computer experience is not a barrier | Women felt acceptance, understanding and relief while using CHESS, | NR | Experienced low levels of negative emotions such as stress, boredom, fear, sadness, indifference, helplessness, and anger,(all less than 3.0) elation and empowerment were low (2.25 and 2.2) while anxiety was high (4.5) | NR | NR | NR | NR | NR | Comparison table given- use of CHESS components by percent of total uses in two study population.
Meigs | 2003 | NR | Hospital based staff resident practice. (The adult Medicine clinic) | Unclear | RCT | N= 598 IVR: 307 CG: 291 | May 1997–April 1999 | NR | NR | NR | NR | NR | TYPE 2 DIABETES | NR | Patients with type 2 Diabetes Grp 1 vs. Grp 2: 44.9% vs. 50.5% | Mean (SD) Grp 1: 68 (±12) Grp 2: 67 (±12) | Grp 1 Caucasian: 71% Black: 19.2% Other: 9.8% Grp 2 Caucasian: 71.1% Black: 18.9% Other: 10.0% | NR | NR | NR | Mean duration of diabetes (SD) Grp 1 vs. Grp 2 ; 9.9 (±5.5) vs. 9.7 (±5.6), p= 0.8 Diabetes therapy % Grp 1 vs. Grp 2 Insulin; 30.6 vs. 36.4, p= 0.1 Oral hypoglycemic medications; 60.9 vs. 63.2, p= 0.6 Diet and exercise only; 17.9 vs. 10.0, p= 0.005 Any lipid lowering medication; 30.9 vs. 38.1, p= 0.06 Any antihypertensive medication; 79.2 vs. 79, p= 1.0 Hyperlipidemia; 56.4 vs. 59.8, p=0.4 Hypertension; 83.1 vs. 76.0, p= 0.03 Smoking; 15.6 vs. 14.8, p= 0.8 Any micro vascular complication; 45.3 vs. 50.2, p= 0.2 Any cardiovascular complication; 52.4 vs. 50.9, p= 0.7 | Payor Commercial < 65 Grp 1: 12.4% Grp 2: 11.0%, p= 0.2 IIMO < 65 Grp 1: 17.6% Grp 2: 19.6% Medicare Grp 1: 60.9% Grp 2: 54.3% Medicaid or other Grp 1: 9.2% Grp 2: 15.1% | NR | NR | NR | Diabetes Disease management Application (DMA) | Web based decision support tool, displaying interactive patient specific clinical data, treatment advice, and links to other web based care resources | Grp 1: received the intervention- DMA provides a single screen view of patient specific information, enabling decision support at the time of patient contact. It displays trended and tabular real time electronic laboratory data interactively linked to evidence based treatment recommendations, facilities to aid encounter work flow, and links to additional patient and provider care resources. Grp 2: not given the intervention- no additional details provided | Computer | Decision support system, links to other resources, Lab data in trended and tabulated form | Staff members were systematically exposed to the intervention, receiving formal pre intervention training and two interactive feedback sessions during the intervention year | NR | NR | Glycemic control outcomes Grp 1 vs. Grp 2 at least one HbA1c test in the last 12 months Preintervention: 264/86% vs. 256/88% Change: +1.6 % vs. - 1.0%, p= 0.3 Mean number of HbA1c tests/year Preintervention: 1.7 (0+.1) vs. 1.8 (+0.1) Change: + 0.3 vs. - 0.04, p= 0.008 HbA1c< 7% Preintervention: 51/21.7% vs. 61/26.6% Change: +1.7% vs. - 2.8%, p= 0.2 Mean HbA1c (% hemoglobin) Preintervention: 8.4 (0.1) vs. 8.1 (0.1) Change: - 0.23 vs. + 0.14, p= 0.09 Cholesterol control outcomes Grp 1 vs. Grp 2 At least 1 LDL chol test, last 12 months Preintervention: 177/57.7% vs. 167/57.4% Change: +7.2% vs. + 3.4%, p= 0.5 Mean number of LDL chol tests /year Preintervention: 0.8 (0.1) vs. 0.9 (0.1) Change: +0.2 vs. + 0.01, p=0.02 LDL chol< 130 mg/dl Preintervention: 62/54.8% vs. 78/63.5% Change: + 20.3% vs. + 10.5% Mean LDL chol (mg/dl) Preintervention: 26.7 (3.1) vs. 122.1 (3.2) Change: -14.7 vs. -9.4, p=0.3 BP control outcomes Grp 1 vs. Grp 2 At least one BP measurement in the past 12 months Preintervention: 299/97.4% vs. 287/98.6% Change: +1.0% vs. - 1.4%, p=0.3 BP < 130/85 (mmHG) Preintervention: 76/25.4% vs. 79/ 29.6% Change: +1.4 % vs. + 2.2 %, p=0.8 Mean systolic BP (mmHg) Preintervention: 138.1 (1.2) vs. 136.9(1.2) Change: + 0.8 vs. -2.2, p=0.03 Mean diastolic BP(mmHg) Preintervention: 78.3 (0.6) vs. 76.4 (0.6) Change: -1.8 vs. -0.8 p= 0.8 (p value comparing baseline characteristics between intervention and control group) At least one eye examination by an eye care professional in the last 12 months Preintervention: 90/29.3% vs. 120/41.2% Change: +5.5% vs. + 1.7% p= 0.5 (p value comparing baseline characteristics between intervention and control group) At least one foot examination in the last 12 months Preintervention: 201/ 65.5% vs. 231/82.1% Change: +9.8% vs. - 0.7% p= 0.003 (p value comparing baseline characteristics between intervention and control group) | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | Preintervention year- diabetic patients N= 1595 Pts exclusions Not in study group: 621 Study patients not seen during intervention year: 225 Clinic chart not found: 36 Patient ineligible: 115 | NR | Demographics related to staff providers given, not listed here Intracorrelation coefficients to assess inter abstractor variability given, not listed here The author also discusses power issues, not given here
Nakagawa | 2000 | Waitlist of OCD patients wanting BT | NR | Homes | Cohort with historical control | N = 43 Grp 1: 23 Grp 2: 20 | NR | 3 weeks | NR | NR | NR | NR | OCD | NR | Gp 1: 49% Gp 2: 55% | Mean Grp 1: 28.6 Grp 2: 27.9 | NR | NR | NR | NR | NR | NR | NR | NR | NR | BT STEPS | Computer driven, telephone interview system using interactive voice response | Group 1: BT STEPS intervention Group 2: Matched waiting list controls | Computer/internet + telephone | Four step self-assessment and five step self-intervention | NR | 5 minutes with coordinator explaining how to use system | NR | NR | Grp 1 completed fewer clinician guided ERP sessions than Grp 2 (8 versus 22) | NR | NR | NR | NR | 9 patients in Grp 1 reported being far more satisfied with the clinician guided ERP versus the BT STEPS (P<0.001) | NR | NR | NR | NR | NR | 3 from Grp 1 2 prior to starting, due to being taken off waiting list and 1 during trial because of marked improvement | NR | NR
Nguyen | 2003 | NR | NR | Homes | Cohort | N= 16 Grp 1: 7 Grp 2: 9 | NR | 3 months | *Subjects in Grp 1: recruited from a database of patients who participated in face-to-face Dyspnoes Self management program (DSMP) *Subjects in Grp 2: recruited from all other sources and had no relationship with the investigators | NR | Yes | NR | YES | NR | NR | Mean (Range) Grp 2: 69.1 (55–82) | NR | NR | NR | NR | NR | NR | NR | NR | NR | iDSMP | *Nurse facilitated and peer supported internet based dyspnoea self management program *Weekly structures self management education via live text chat *Exercise monitoring, goal setting and feedback *Pulmonary function and symptom monitoring (pts monitor lung function with air watch and data uploaded into the site *Peer and professional communication via chats, bulletin boards, email | Grp 1: pts from database who participated in Face to Face DSMP allowing a test of booster effect Grp 2: iDSMP - no relationship with investigator in order to evaluate the program as primary intervention Home visits conducted and process metrics tracked | Computer | Communication, chat, emails, symptom monitoring, self management education | NR | NR | NR | FEV1/FVC: 41 +/- 7% Improvements noted for Dyspnoea (effect size=0.86) Endurance exercise 0.27 for the overall sample | NR | NR | NR | First month registered most logins (330) compared to 104 in the final month | NR | NR | NR | Improvement in self efficacy for managing dyspnoea = 0.94 | NR | NR | Support: 0.32 | NR | NR | NR
Nguyen | 2005 | Grp 1: was recruited from a pool of individuals who previously participated in a face-to-face DSMP, which would allow testing of a “booster” effect. Grp 2: recruited from all other sources (pulmonary practices, Better Breather groups, pulmonary rehabilitation programs, and online COPD groups) | NR | Homes | Nonrandomized between group | N = 23 Grp 1: 12 Grp 2: 11 | NR | 3 months | *Active use of a computer and Internet/web *Diagnosis of COPD (bronchitis emphysema, irreversible asthma) *ADL limited bydyspnea *Approval from a health provider to start an exercise program *Ability to speak and write English *Resident of the San Francisco Bay area or southern California. | NR | Yes | YES | COPD | NR | N = 50% | Mean (SD) 69.1 (±7.0) Range: 55–82 | African-American: 1pt (6%) Caucasian: 13pts (81%) Native American: 1pt (6%) Other: 1pt (6%) | NR | High school: 4pts (25%) Some college: 4pts (25%) College or greater: 8pts (50%) | NR | 81% retired or disabled | NR | NR | English | NR | Dyspnea Self-Management Program | Website to help individuals with COPD better manage their condition by being informed of activities that help or exacerbate their condition | Group 1: “boosters” had previously participated in some DSMP Group 2: Primary intervention, no prior DSMP | Dyspnea Self-Management Program | Logon to website at least 3 times/week, 2 weekly chat sessions, online bulletin board and email support, individualized exercise plans | NR | 1–2 hours of in home training on web site and spirometry device | AirWatch spirometer | P-values CRQ Dyspnea Grp 1 vs. Grp 2: 0.86 Pooled sample: 0.005 Dyspnea Distress Grp 1 vs. Grp 2: 0.25 Pooled:0 .48 Dyspnea impact Grp 1 vs. Grp 2: 0.43 Pooled: 0.48 | NR | NR | NR | NR | NR | NR | NR | Self efficacy for managing dyspnea 1 vs. 2: .38 pooled: .009 CRQ Mastery 1 vs. 2: .08 pooled: .14 | Exercise, self-report, Measured with Medical Outcomes Study SF-36 | NR | NR | N=8 Group 1: 2 were too busy,1 overwhelmed, 3 sporadic participation Group 2: 1 dropped due to computer failure, 1 died of pneumonia | Computer issues included hand trembles for 3 individuals and paralysis for one, all of whom were able to accommodate their limitations (e.g., using a different mouse). Stiff necks. Patients were sent to a reputable site for computer stretches. | NR
Noel | 2004 | NR | VA system | Homes | single blind single site randomized trial | N=104 Grp 1 (IVR): 47 Grp 2 (CG): 57 | NR | 6–12 months | *Documented high use of healthcare resources and barriers to accessing healthcare services due to geographic, economic, physical, linguistic, technological, and/or cultural factors *Pts met these criteria and had been actively receiving nurse case management for at least 6 months preceding the study and during the study | NR | NR | NR | DM, CHRONIC LUNG DISEASE, COMPLEX CHF | NR | Total= 97% IG: 42% CG: 55% | Mean Total= 71 IG: 72 CG: 70 | NR | NR | NR | NR | One morbidity (%), Total vs. IG vs. CG CHF: 57 vs. 30 vs. 27 COPD: 35 vs. 16 vs. 17 DM: 56 vs. 24 vs. 32 Two co morbidities (%), Total vs. IG vs. CG CHF+COPD: 21 vs. 12 vs.10 CHF+DM: 34 vs. 13 vs. 11 COPD+DM: 13 vs. 6 vs. 7 Three co morbidities, Total vs. IG vs. CG CHF+COPD+DM: 11 vs. 6 vs. 5 | NR | NR | NR | NR | Home telehealth unit | Home telehealth units used standard phone lines to communicate with the hospital. FDA approved peripheral devices monitored vital signs and valid questionnaires were used to evaluate quality of life outcomes with out of range data triggering alerts. | The CG received usual home health care services plus nurse case management IG received home telehealth plus nurse case management Home telehealth- user friendly devices with a touch screen interface and step by step instructions using graphics, large text and audio. FDA approved peripheral devices plug into telehealth unit and collect data for temperature, blood pressure, pulse, blood glucose, 3 lead ECG, stethoscope for heart and lung sounds, pulse oximetry and weight, pain level is self reported; data transmitted through telephone lines to VACT's web based intranet system and directly into the facility's electronic database; digital camera used to monitor wound care images; disease specific patient education modules include pass/fail tests to demonstrate learning achieved. | Home telehealth device | Data input, alerts, disease specific education modules, on screen assessment surveys | NR | NR | NR | Diabetic A1C levels; Mean (SD); Baseline IG: 8.30 (±1.61) CG: 7.03 (±1.08) Between groups; t=+3.233,p=0.003, z=0.004 6 months IG: 7.3 (±1.47), t= + 4.242, p=0.0001, z=0.001 CG: 7.83 (±1.65), - 3.398, p=0.002, z=0.006 Between groups; t= - 1.228, p=0.225, z=0.260 | Bed days of care (BDOC): Total (n=64) vs. IG (n=26) vs. CG (n=38) Pre: 842 vs. 317 vs. 525 Post: 243 vs. 49 vs. 194 Total visits: Total (n=102) vs. IG (n= 46) vs. CG (n=56) Pre: 1613 vs. 682 vs. 931 Post: 1520 vs. 682 vs. 838 Urgent visits: Total (n=98) vs. IG (n=44) vs. CG (n=54) Pre: 622 vs. 320 vs. 302 Post: 544 vs. 237 vs. 307 Coumadin visits: Total (n=26) vs. IG (n=11) vs. CG (n= 15) Pre: 187 vs. 79 vs. 108 Post: 146 vs. 82 vs. 64 RN home visits: Total (n= 21) vs. IG (n=12) vs. CG (n=9) Pre: 223 vs. 119 vs. 104 Post= 197 vs. 94 vs. 103 Cost variables, Mean (SD): VA and non VA BDOC Baseline IG: 12.19 (±11.95) CG: 13.82 (±10.27) Between groups: t= - 0.564,p=0.575, z=0.295 6 months IG: 1.88 (±3.33), t= 4.902, p=0.0001, z=0.0001 CG: 5.11 (±10.54), t=3.656, p=0.001, z=0.0001 Between groups: t= - 1.760, p=0.085, z=0.495 Total clinic visits, Mean (SD): Baseline IG: 14.51 (±10.49) CG: 16.33 (±14.60) Between groups; t= - 0.727,p=0.469, z=0.496 6 months IG: 14.83 (±11.28), t= 0.000, p=1.000, z=0.831 CG= 14.96 (±15.09), t= 1.137, p=0.260, z=0.042 Between groups: t= - 0.053, p=0.958, z=0.609 Urgent visits, Mean (SD): Baseline IG: 7.27 (±5.12) CG: 5.59 (±4.69) Between groups; t= 1.676,p=0.097, z=0.055 6 months IG= 5.39 (+5.50), t= 2.364, p=0.023, z=0.003 CG= 5.69 (+6.0), t= - 0.124, p=0.902, z=0.898 Between groups: t= - 0.257, p=0.798, z=0.701 RN home visits, Mean (SD): Baseline IG: 2.53 (±5.90) CG: 1.82 (±5.19) Between groups: t=0.642,p=0.522, z=0.487 6 months IG: 2.00 (±4.60), t= 0.660, p=0.512, z=0.563 CG: 1.81 (±5.66), t= 0.027, p=0.979, z=0.953 Between groups: t= 0.192, p=0.848, z=0.377 | Cost item ($): IG vs. CG RN/home visits Pre study: 11, 067 vs. 9,672 Post study: 8,742 vs. 9,579 BDOC Prestudy: 273,918 vs. 567,126 Post study: 46,296 vs. 204,474 Coumadin Pre study: 1,185 vs. 1,620 Post study: 1,230 vs. 960 Total visits Pre study: 34,100 vs. 46,550 Post study: 34,100 vs. 41,900 Urgent visits Pre study: 16,000 vs. 15,100 Post study: 11,850 vs. 15,350 Transport (VA costs) Prestudy: 35,811 vs. 44,816 Post study: 32,258 vs. 40,538 Transport, cost patient Prestudy: 18,186 vs. 22,759 Post study: 16,381 vs. 20,586 Telehealth unit IG: 78,302 Total cost/participant Pre study: 8,278 vs. 12,386 Post study: 4,849 vs. 5,832 | NR | NR | NR | NR | QoL-self rated health status, M (SD) Baseline, IG (n)= 47, CG (n)=57 Between grps; p= 0.207, z= 0.208 IG: 81.32 (±13.07) CG: 84.86 (±15.33) 3 months, IG (n)= 47, CG (n)= 57 Between groups; p= 0.755, z= 0.590 IG: 81.34 (±13.71), p= 0.984, z= 0.728 CG: 82.25 (±15.83), p= 0.070, z=0.129 6 months, IG (n)= 47, CG (n)= 57 Between groups; p= 0.353, z= 0.296 IG: 82.47 (±12.89), p= 0.447, z= 0.392 CG: 85.14 (±16.28), p= 0.885, z=0.944 9 months, IG (n)=15, CG (n)= 27 Between groups; p= 0.596, z= 0.763 IG: 84.40 (±13.23), p= 0.980, z= 0.776 CG: 82.11 (±13.34), p= 0.757, z=0.893 12 months, IG (n)=8, CG (n)= 14 Between groups: p= 0.506, z= 0.616 IG: 88.00 (±22.16), p= 0.110, z= 0.159 CG: 82.21 (±10.81), p= 0.150, z=0.124 | NR | NR | QoL -Cognitive status, M (SD) Baseline, IG (n)= 47, CG (n)=57 Between grps: p= 0.751, z= 0.844 IG: 19.31 (±1.71); CG: 19.42 (±1.51) 3 months, IG (n)= 47, CG (n)= 57 Between groups: p= 0.578, z= 0.440 IG: 19.62 (±1.06), p= 0.227, z= 0.123 CG: 19.46 (±0.169), p= 0.699, z=0.341 6 months, IG (n)= 47, CG (n)= 57 Between groups: p= 0.921, z= 0.157 IG: 19.70 (±1.06), p= 0.115, z= 0.056 CG: 19.68 (±0.69), p= 0.171, z=0.135 9 months, IG (n)=15, CG (n)= 27 Between groups: p= 0.234, z= 0.441 IG: 19.80 (±0.414), p= 0.028, z= 0.034 CG: 19.56 (±0.892), p= 0.032, z=0.074 12 months, IG (n)=8, CG (n)= 14 Between groups: p= 0.006, z= 0.019 IG= 20 (±0.00), p= 0.095, z= 0.102 CG= 19.43 (±0.646), p= 0.635, z=0.763 QoL -Functional, M (SD) Baseline, IG (n)= 47, CG (n)=57 Between grps: p= 0.035, z= 0.04 IG: 37.02 (±9.25); CG: 40.19 (±4.47) 3 months, IG (n)= 47, CG (n)= 57 Between groups: p= 0.780, z= 0.058 IG: 37.17 (±9.15), p= 0.801, z= 0.601 CG: 39.88 (±5.38), p= 0.546, z=0.959 6 months, IG (n)= 47, CG (n)= 57 Between groups: p= 0.146, z= 0.073 IG: 37.91 (±9.22), p= 0.138, z= 0.162 CG: 40.19 (±5.81), p= 1.00, z=0.558 9 months, IG (n)=15, CG (n)= 27 Between groups: p= 0.195, z= 0.125 IG: 38.67 (±5.63), p= 0.646, z= 0.624 CG: 40.96 (±4.83), p= 0.597, z=0.452 12 months, IG (n)=8, CG (n)= 14 Between groups: p= 0.799, z= 0.868 IG: 37.63 (±6.21), p= 0.107, z= 0.089 CG: 38.29 (±4.78), p= 0.417, z=0.440 QoL -patient satisfaction, M (SD) Baseline, IG (n)= 47, CG (n)=57 Between grps: p= 0.154, z= 0.066 IG: 103.55 (±17.54); CG: 98.70 (±16.63) 3 months, IG (n)= 47, CG (n)= 57 Between groups: p= 0.001, z= 0.001 IG: 110.8 (+18.32), p= 0.001, z= 0.001 CG: 98.98 (+17.24), p= 0.825, z=0.834 6 months, IG (n)= 47, CG (n)= 57 Between groups: p= 0.020, z= 0.018 IG: 106.38 (±20.99), p= 0.226, z= 0.335 CG: 97.14 (±18.22), p= 0.403, z=0.819 9 months, IG (n)=15, CG (n)= 27 Between groups: p= 0.110, z= 0.152 IG: 109.13 (±23.21), p= 0.454, z= 0.451 CG: 98.11 (±16.58), p= 0.032, z=0.074 12 months, IG (n)=8, CG (n)= 14 Between groups:; p= 0.125, z= 0.110 IG: 109.75 (±21.40), p= 0.427, z= 0.574 CG: 95.57 (±14.74), p= 0.004, z=0.006 | NR | The author says that there was diminishing participation beyond 6 months but no more details given | NR | Cognitive status showed significant improvement at 12 months for the few remaining participants in the IG Telehealth added $ 1666 to outcome costs during the 6 months of study Healthcare costs decreased by 58% for the telehealth grp and 47% for the CG.
Owen | 2005 | NR | Hematology/Oncology outpatient clinic at a large medical center in the US | Homes | Randomized wait-list control | N = 62 CG: 30 IVR: 32 | NR | 3 mos | At the outset: *Women with histological confirmed clinical stage 1 or 2 breast cancer After randomization: *Small number of pts were stage 0 or stage 3 and because of their strong desire to participate, were included in the study | Recruitment efforts are described in detail in another study (Owen, Klapow, Roth) | NR | NR | BREAST CANCER | NR | N = 0% | Mean (SD) CG: 51.3 (±10.5) IG: 52.5 (±8.6) | Caucasian CG: 100% IG: 95.8% | Mean Annual Income (SD) CG vs. IG CG: $65,000 (±$24,407) IG: $65,000 (±$114,148) | Mean years (SD) CG: 15.3 (±2) IG: 15.8 (±2.2) | NR | Marital status (% Married) CG vs. IG 77.8 vs. 87.5 Distance to clinic (miles)- Mean (SD) CG vs. IG 55.2 (66.3) vs. 107.5 (301.5) Employment status (%) Employed full time-CG vs. IG----- 46.7 vs. 42.9 Employed part time-CG vs. IG------16.7 vs. 14.3 Not employed- CG vs. IG--------36.6 vs. 42.8 Time since diagnosis (months) mean (SD) CG vs. IG--- 31.8(37.6) vs. 23.2 (28.4) Breast conserving surgery (%) CG vs. IG----- 33.3 vs. 27.8 Modified radical mastectomy (%) CG vs. IG---------- 60 vs. 63.9 Treated with radiation(%) CG vs. IG------------53.3 vs. 47.1 Treated with chemotherapy(%) CG vs. IG---------------- 63.3 vs. 85.3 There is also data on clinical stage of the disease, positive lymph nodes outside the breast and use of complementary or alternative medicine- not listed here | NR | NR | NR | NR | Survive website | Self guided, internet based coping skills training given to pts in the intervention group | IG: provided with bulletin board for asynchronous group discussions, a dictionary of medical terminology, a database of breast cancer resources and websites, information and coping advice for management of common physical symptoms, a forum for sharing artwork and poetry, and six structured coping skills exercises. They were identification of passive and active coping styles; communication with family and friends; identification of relationships among stress, emotions and behavior; stress management training; assertiveness training; structured problem solving training They also received 39 prompts sent by email summarizing a coping skill exercise and suggesting that the pts post a message to the group to discuss experiences with each. | Computer | Discussion groups, bulletin boards, forum, email | NR | Pts were given brief instructions on using the website | NR | NR | NR | NR | NR | Average total log ins to the website: 35.5 Hits to the bulletin board: 52.2 Postings sent to the bulletin board: 9.5 Uses of the coping exercises: 73.4 Hrs spent logged in to the website: 3.4 Mins per session over the course of 12 week intervention: 8.2 | NR | Coping exercises found most helpful: 68.2% Coping group/bulletin board: 59.1% Information about coping with specific symptoms: 57.2% Either the coping exercises or discussion group was helpful: 82% | NR | NR | NR | Health related quality of life FACT-Total measure CG vs. IG Pre M (SD) = 81(14.3) vs. 78.3(15.7) post M (SD) = 85.3(11.8) vs. 88.7(10.8) F value- grpX baseline interaction effect- 0.33 (1,45) Treatment effect size- 0.30 EQ-5D thermometer CG vs. IG Pre M (SD) = 78.4 (17.2) vs. 75.6(20.2) post M (SD) = 83.5(17.1)vs. 85.4 (9.9) F value- grpX baseline interaction effect- 16.40 (1,39), p<0.001 Treatment effect size- 0.13 Psychological wellbeing FACT- EWB CG vs. IG Pre M (SD) = 15.4(4.0) vs. 14.8(3.9) post M (SD) = 15.3 (3.6) vs. 16.5(2.6) F value- grpX baseline interaction effect- 1.00 (1,45) Treatment effect size- 0.38, p <0.10 IES Total CG vs. IG Pre M (SD) = 0.96(0.6) vs. 1.10(0.6) post M (SD) = 0.95(0.7) vs. 0.95(0.6) F value- grpX baseline interaction effect- 1.63 (1,47) Treatment effect size- 0.00 Physical wellbeing MSAS symptom prevalence CG vs. IG Pre M (SD) =10.9 (7.4) vs. 11.6(7.6) post M (SD) = 8.7(6.2) vs. 8.4 (6.3) F value- grpX baseline interaction effect-1.85 (1, 41) Treatment effect size-0.05 FACT- Breast specific concerns CG vs. IG Pre M (SD) = 23.1 (5.8) vs. 22.2 (6.5) post M (SD) = 23.9 (6.3) vs. 25.5 (4.8) F value- grpX baseline interaction effect- 2.17 (1, 48) Treatment effect size- 0.28 | NR | Pts expressing interest in the study- 154 Excluded- 59 (not interested any more, lack of familiarity with computer, participating in a competing trial, could not be reached by phone) Did not complete baseline assessment- 33 Randomized- 62, IG=30 (Received intervention-30; did not participate in intervention, never logged in- 5) Loss to follow up=6 (could not be reached or unwilling to complete follow up assessment) Analyzed=26 (excluded from analysis due to incomplete follow up-6) CG= 30 Loss to follow up= 3 (could not be reached or unwilling to complete follow up assessment) Analyzed= 27 (excluded from analysis due to incomplete follow up data=3) Cross over into intervention group= 18 declined to participate= 11 | NR | Pts motivation for enrolling in the study given, not listed here There is a graph showing use of each component of the intervention over time A table showing Pearson correlation coefficients between linguistic variables associated with messages and change scores on dependent variables given, not listed here
Piette | 1997 | NR | PAVA Diabetes care clinic, Endocrinology clinic, General Internal Medicine clinic | Homes | Cohort | N= 65 | NR | NR | *Pts with diagnosis of IDDM or NIDDM *Proficient in English | Pts excluded if psychotic, demented or blind as determined by the diagnosis in the medical record, resided in a congregate care facility, or did not have a working touch tone telephone in their home. | NR | NR | DIABETES | NR | N = 62 (92.4%) | Range ≤55: 15 pts 55–64: 20 pts ≥65: 30 pts | [underlined: Total] Caucasian: 61.5% Black: 9.2% Hispanic: 18.5% Asian/Pacific Islander: 10.8% Low income % in the groups [underlined: ≤55 yrs] Caucasian: 66.7% Black: 6.7% Hispanic: 26.7% Hispanic [underlined: 55– 64 yrs] Caucasian: 50% Black: 20% Hispanic: 20% Asian/Pacific Islander: 10% [underlined: ≥65+ yrs] Caucasian: 66.7% Black: 3.3% Hispanic: 13.3% Asian/Pacific Islander: 16.7 % [underlined: Pts taking insulin] Caucasian: 55.6% Black: 7.4% Hispanic: 33.3% Asian/Pacific Islander: 3.7% [underlined: Pts not taking insulin] Caucasian: 65.8% Black: 10.5% Hispanic: 7.9% Asian/Pacific Islander: 15.8% | VA eligible due to low income: 46.9% Low income: <55 yrs: 43% 55–64 yrs: 38.9% 65≤ yrs: 53.1% Taking insulin: 46.1% Not taking insulin: 47.4% | NR | NR | Marital status- 53.1% Married, 45.3% not married, 1.6% not applicable Marital status in the groups Less than 55 yrs- 50% married, 42.9% not married, 7.1% not applicable 55–64 yrs- 50% married, 50% not married, 65 + yrs- 56.3% married, 43.7% not married Taking insulin- 46.2% married, 50.0% not married, 3.8% not applicable Not taking insulin- 57.9% married, 42.1% not married Employment status-10.9% full time employed, 67.2% unemployed/retired, 21.9% other Employment status in the groups Less than 55 yrs- 21.4% full time employed, 64.3 % unemployed/retired, 14.3% other 55–64 yrs- 5.5% full time employed, 77.8% unemployed/retired, 16.7% other 65 + yrs- 9.4% full time employed, 62.5% unemployed/retired, 28.1% other Taking insulin- 10.5% full time employed, 71.1% unemployed/retired, 18.4% other Not taking insulin- 11.5% full time employed, 61.6% Unemployed/retired, 26.9% other Yrs since diagnosis less than or equal to 2 yrs- 21.5% 3–10 yrs= 43.1% 11 + yrs= 35.4 % yrs since use given, not listed here) (subgroup analysis of Using insulin= 41.5% | NR | NR | NR | NR | Automated voice messaging system (AVM) | AVM system using specialized computer technology to telephone patients, communicate messages, and collect information | n= 65 pts AVM calling protocol designed: *to inquire about diabetic symptoms that may be prognostic of poor glucose control and adverse health outcomes *to inquire about pts problems with glucose monitoring and foot care, *to inquire about adherence to diet and medication schedule and *to give pts the option of listening to health promotion messages regarding diabetic eye care, foot care, cardiovascular health and management of sick days. Pts reporting serious problems reached within 48 hrs. At the end of each AVM call, pts instructed to call the PAVA Out patient clinic about health or health care (contact number provided) | Telephones | Messages, information/education, storage of data. | NR | NR | NR | Reported health problems Chest Pain < 55 yrs= 20%, 55–64 yrs= 30%, 65+ = 26.7%, Taking insulin= 23.7%, Not taking insulin= 23.7%, Total= 26.2% Foot problems < 55 yrs= 33.3%, 55–64 yrs= 10%, 65+ = 10%, Taking insulin= 22.2%, Not taking insulin= 15.8%, Total= 18.5% Poor glucose control < 55 yrs= 33.3%, 55–64 yrs= 15%, 65+ = 13.3%, Taking insulin= 25.9%, Not taking insulin= 13.2%, Total= 18.5% Hypoglycemic symptoms, p< 0.05 < 55 yrs= 66.7%, 55–64 yrs= 35%, 65+ = 26.7%, Taking insulin= 55.6%, Not taking insulin= 26.3%, Total= 38.5% Hyperglycemic symptoms < 55 yrs= 60%, 55–64 yrs= 50%, 65+ = 36.7%, Taking insulin= 59.3%, Not taking insulin= 36.8%, Total= 46.2% Poor health < 55 yrs= 20%, 55–64 yrs= 10%, 65+ = 10%, Taking insulin= 18.5%, Not taking insulin= 7.9%, Total= 12.3% Reported self care problems Glucose monitoring < 55 yrs= 16.7%, 55–64 yrs= 44.4%, 65+ = 38.9%, Taking insulin= 18.5%, Not taking insulin= 34.2%, Total= 27.7% Foot care < 55 yrs= 20%, 55–64 yrs= 45%, 65+ = 50%, Taking insulin= 40.7%, Not taking insulin=42.1%, Total= 41.5% Medication adherence < 55 yrs= 40%, 55–64 yrs= 23.5%, 65+ = 25%, Taking insulin= 22.2%, Not taking insulin= 30.3%, Total= 27.5% Diet adherence < 55 yrs= 40%, 55–64 yrs= 29.3%, 65+ = 17.4%, Taking insulin= 42.1%, Not taking insulin= 16.1%, Total= 26% | NR | Human calling system-generate 390,000 calls/yr, Assuming 10 mins/call, 26 full time staff required at more than $ 1.2 million /yr. AVM system with multiple phone lines-(costing around $ 90,000) and one all time nurse (costing around $ 22,500) for a total cost of $112,500. (around 10% of human calling system) Assuming system paid for in the first year, program cost for 2nd year would be $ 22,500 ($3/pt) or 2% of the cost of the human calling program | NR | NR | NR | Listened to 2+ preventive messages < 55 yrs: 37.5% 55–64 yrs: 74.4% ≥65: 85.6% Taking insulin: 71.5% Not taking insulin: 70% Total: 70.6% Reported AVM was helpful < 55 yrs: 92.9% 55–64 yrs: 100% ≥65: 100% Taking insulin: 94.7% Not taking insulin: 100% Total: 98.1% No difficulty responding < 55 yrs: 100% 55–64 yrs: 100% ≥65: 95.7% Taking insulin: 95.2% Not taking insulin: 100% Total: 98.1% Would like to receive AVM < 55 yrs: 100% 55–64 yrs: 82.4% ≥65: 87.5% Taking insulin: 95% Not taking insulin: 84.4% Total: 88.5% AVM would make them more satisfied with VA care <55 yrs: 90.9% 55–64 yrs: 72.2% ≥65: 75.0% Taking insulin: 81.0% Not taking insulin: 75.0% Total: 77.4% | NR | NR | NR | NR | NR | Potential eligible pts: 74 Ineligible: 4 Difficulty understanding English: 1 Had memory deficit: 1 Asked to withdraw because he was dissatisfied with the AVM calls: 1 Final sample: 65 pts (2 not accounted for by the author) | NR | Pts ability to respond to AVM calls given, not reported here
Pike KJ | 2007 | American Cancer Society website | NA | WWW | Randomized trial | N = 6451 6 randomized groups CG: Break Away from the Pack static website with pdf self-help files Grp 1: Oregon Center for Applied Science Grp 2: ProChange Grp 3: QuitNet Grp 4: Smoke Clinic Grp 5: Centre for Addiction & Mental Health | October 2004 – May 2005 | 3 months | *Visitors to ACS website responding to online recruitment for study *English speaking *Smoke daily *U.S. residents *Complete online informed consent and intake questions | NR | NR | NR | SMOKING | NR | N = 30% | Mean: 41 | Caucasian: 87% | NR | Some college: 75% | NR | 21% use the Internet daily and 66% use Internet more than once/day | NR | English literate | NR | NR | Control: pdf files; ORCAS: tailored presentations with role models; ProChange: tailored feedback on stage of change; QuitNet: personalized content and group support; Smoke Clinic: structured assessment with relapse prevention; Centre for Addiction & Mental Health: tailored content and group support with RN moderated discussion | Subjects randomized to use one of 6 websites described above | NR | NR | NA | NA | NR | NR | NR | NR | NR | NR | “Wide variation” in individual website use; 3 sites had higher use (20% or more subjects making 5 or more visits) and 3 had lower use (<10% make 5 or more visits) High vs. low site use Non-ITT quitting: 26% vs. 22.1% | NR | NR | NR | NR | Self-reported, 7-day point prevalence of quitting at 3 months: CG: 22.3% control Exp Grp: 23.5% Intent-to-treat (54% response; assume non-responders smoking): CG: 10.9% Exp Grp: 11% | NR | NR | 46% non-response to follow-up survey (online with phone f/u) | NR | NR
Rami | 2006 | NR | NR | Homes | Randomized cross over trial | N= 36 Telemedicine-PaperDiary group: 18 PD-TM: 18 | NR | 6 months | *HbA1c ≥8% *Duration of disease >1 year *Age between 10–19 yrs *Willingness and consent to participate in the study *Willingness to attend follow up visits every 3 months | NR | NR | NR | DIABETES-Type 1 | NR | TM-PD Grp: 50% PD-TM Grp: 61% | TM-PD: 14.5 (12.9–19.3), NS PD-TM: 16.2 (10.7–19.0), NS | NR | NR | NR | NR | TM-PD vs. PD-TM Duration of diabetes (yrs) 6.4 (1.0–12.8) vs. 6.1 (2.9–11.1), NS BMI 19.0 (15.9–32.6) vs. 17.8 (18.4–28.7), NS HbA1c at start (%) 9.1 (8.0–11.3) vs. 9.3 (8.3 – 11.6), NS | NR | NR | NR | NR | VIE-DIAB system | Feasibility study of a telemedicine support system (VIE-DIAB) and its effect on glycemic control in adolescents with TIDM VIE-DIAB collects and processes data on glycemic control received from mobile phone services (SMS, GPRS, WAP) and from password protected internet connection to the server, daily serum glucose concentrations glyphs displays, once a week automatically generated SMS or personalized message with advice. | TM VIE-DIAB collects and processes data on glycemic control received from mobile phone services (SMS, GPRS, WAP) and from password protected internet connection to the server such as date and time, serum glucose value, insulin dosage, carbohydrate intake, and additional notes. daily serum glucose concentrations glyphs displays, once a week automatically generated SMS or personalized message with advice PD Routine scheme with a daily written protocol | Mobile phones | SMS, data log, free text, serum glucose levels, on screen tailored glyphs | NR | Pts instructed to measure 4 blood glucose values/day All pts informed about technical features of the program, of SMS communications, and all pts received a manual containing these instructions. | NR | Glycemic control improved during TM stage, p<0.05 At the end of the study, HbA1c values reached the same endpoint TM-PD vs. PD-TM; median (range) 9.2 (7.4–12.6) vs. 8.85 (7.3–11.7%) | NR | Telecommunication costs was low | NR | NR | NR | Overall satisfaction good Pts mainly criticized the additional workload and GPRS access problems- because of these problems, pts rated the system time consuming and only half of them wanted to continue with the system Table showing results of pt satisfaction survey given, not listed here | NR | NR | NR | NR | NR | NR | NR | NR
Rasmussen | 2005 | Catchment area of H:S Bispebjerg university hospital | Asthma specialist clinic, GP clinic | Homes | Prospective randomized comparative design (prospective RCT) | N=300 Internet Grp: 100 Specialist Grp: 100 GP Grp: 100 | NR | 6 months | *Combination of respiratory symptoms and at least 1 objective measure of asthma viz *Airway hyper responsiveness to inhaled methacholine less than or =4 μmol *Peak expiratory flow variability (PEF) of equal to or more than 20% and/or minimum of 15% (300mL) increase in FEV1 after bronchodilation | NR | NR | NR | ASTHMA | NR | Grp 1: 27% Grp 2: 30% Grp 3: 30% Withdrawals: 14% | Mean (Range) Grp 1 : 28 (18–44) Grp 2 : 30 (19–45) Grp 3 : 30 (20–45) | NR | NR | NR | Catchment area | NR | NR | NR | NR | NR | Physician managed online interactive asthma monitoring tool | Electronic diary, action plan for patients, decision support system for physician Pts given a peak flow meter, pts record symptoms, need for rescue medication and PEF values. 3 colored warning system with written action plan Pts fill diary daily and follow instructions given by computer and physician Check online repository at www.mosby.com/jaci | Grp 1: Internet group Grp 2 : Specialist group Grp 3 : GP group Grp 1: details given above, also check online Grp 2: Pts treated acc to severity and taught how to adjust medication, pts given peak flow meter and written action plan that had a 3 color warning system based on symptom score and PEF values Grp 3: Pts asked to contact GP with letter describing study and test results. GP to assess symptoms and tests and decide need for pharmaceutical treatment. pts did not receive treatment or info from study physician | Computer, push-button telephone | Electronic asthma diary, daily recordings of symptoms, PEF values, instructions from physician, decision support for physicians-check online journal | None specified as such- but all GPs received a circular about asthma and GINA guidelines by local authority | Pts instructed in the use of internet diary, pts in SP group taught medication adjustment | NR | Improved symptoms -Odds Ratio (95% CI) Grp 1 vs. Grp 2: 2.64 (1.43–4.88), p= 0.002 Grp 1 vs. Grp 3: 3.26 (1.71–6.19), p < 0.001 Grp 2 vs. Grp 3: 1.23 (0.66–2.30), p= NS Improved AQLQ score(Asthma quality of life questionnaire) Odds ratio (95% CI) Grp 1 vs. Grp 2: 2.21 (1.09–4.47), p= 0.03 Grp 1 vs. Grp 3: 2.10 (1.02–4.31), p = 0.04 Grp 2 vs. Grp 3: 0.95 (0.43–2.07), p= NS Improved FEV1 more than or equal to 300 mL Odds ratio (95% CI) Grp 1 vs. Grp 2: 3.26 (1.50–7.11), p= 0.002 Grp 1 vs. Grp 3: 4.86 (1.97–11.94), p <0.001 Grp 2 vs. Grp 3: 1.49 (0.55–4.05), p= NS Improved AHR (airway hyper responsiveness) Odds ratio (95% CI) Grp 1 vs. Grp 2: 1.26 (0.57–2.79), p= NS Grp 1 vs. Grp 3: 3.06 (1.13–8.31), p =0.02 Grp 2 vs. Grp 3: 2.44 (0.89–6.72), p=NS Improvements in FEV1 in 6 months Grp 1 vs. Grp 2 vs. Grp 3: 0.187mL (SEM 0.04) vs. 0.035 mL(SEM 0.03) vs. 0.004mL (SEM 0.03) Additional analyses provided in online repository | Acute unscheduled visits by % pts on a monthly basis Grp1 vs. Grp 2 vs. Grp 3 3.7% vs. 2.1% vs. 1.3% (P= 0.05, chi sq) GP group visited physician on avg once (95th percentile, 1–3) Internet grp: used tool on avg 4 times in 2 week block (range, 1–6) Sp group: 1 pt hospitalized due to exacerbation more data on the website | NR | NR | Pts in Internet group used tool on average 4 times in 2-week blocks Range: 1–6 | NR | NR | NR | NR | No asthma Medication Grp 1 (baseline: FU, Mcnemar) vs. Grp 2 (baseline: FU, Mcnemar) vs. Grp 3 (baseline : FU, Mcnemar) 44%:0%, <0.001 vs. 57% :1%, <0.001 vs. 53% : 26%, <0.001 Take Inhaled corticosteroids Grp 1 (baseline: FU, Mcnemar) vs. Grp 2 (baseline: FU, Mcnemar) vs. Grp 3 (baseline : FU, Mcnemar) 21% : 91%, <0.001 vs. 20% : 83%, < 0.001 vs. 17% : 29%, 0.04 Good Compliance Grp 1 (baseline: FU, Mcnemar) vs. Grp 2 (baseline: FU, Mcnemar) vs. Grp 3 (baseline : FU, Mcnemar) 32% :87%, <0.001 vs. 25% :79%, <0.001, 36%:54%, <0.001 Use of action plan Grp 1 (baseline: FU, Mcnemar) vs. Grp 2 (baseline: FU, Mcnemar) vs. Grp 3 (baseline : FU, Mcnemar) +E42% :88%, <0.001 vs. 3%:66%, <0.001 vs. 0% : 6%, NS | NR | NR | N = 47 Grp 1: 15 Grp 2: 12 Grp 3: 20 no significant difference in the dropout rate, P= 0.26, chi sq | Grp1 vs. Grp 2 vs. Grp 3 Dysphonia: 17% vs. 4% vs. 9% Oropharyngeal candidiasus: 18% vs. 3% vs. 4% | Pts characteristics at baseline given, not listed here Viz- symptoms grading AQLQ scores FEV1, % predicted AHR
Reid RD | 2007 | University of Ottawa Heart Centre | Hospital to Home | Homes | RCT | N = 100 IVR: 50 CG: 50 | November 2004 – May 2005 | 12 months | *Smoke 5 or more cig/day, *Age 18+ *Hospitalized for acute coronary syndrome or catheterization or percutaneous coronary intervention (PCI) | Live 1 hour or more away | NR | NR | SMOKING | NR | IVR: 61% CG: 74% | Mean IVR: 54 CG: 53.9 | NR | NR | High school IVR: 91% CG: 70% More than HS IVR: 9% CG: 30% | NR | NR | NR | NR | NR | NR | NR | All subjects: inpatient bedside counseling by nurse specialist and nicotine therapy, if needed. Experimental: IVR contact post-discharge on day 3, 14 and 30. IVR queries on smoking status, confidence in quitting, use of pharmacotherapy, use of self-help; If subject wanted to quit or had confidence <7 (out of 10), nurse counselor called 3 times over 8 week period. | IVR or Usual Care | Telephone | Subject responses to IVR flag a counselor to call | NR | NR | NR | NR | NR | NR | NR | IVR contact 3 days: 35/50 14 days: 36/50 30 days: 34/50 | NR | NR | NR | NR | Self-report not smoking at 52 weeks: unadjusted: IVR: 46% CG: 34.7% (OR 1.6, CI 0.7–3.6, p=0.25) Adjusted for age, education, diagnosis, prior quitting: OR 2.34, CI 0.92–5.92, p=.07) | NR | NR | 1 control subject died | NR | NR
Robertson | 2006 | NR | One public hospital and public and private clinics | Homes | Cohort | N= 144 | NR | 12 mos | *Currently receiving treatment for depression under the care of a mental health professional *Previously or currently satisfying the diagnostic criteria for a major depressive episode *Access to a computer and the internet *Willing to use the internet as a part of the treatment *Willing to provide informed consent *Sufficient cognitive functioning *Proficiency in English *Age ≥ 18 yrs | NR | NR | NR | DEPRESSION | NR | N = 37.5% | Mean (Range): 42 (19–64) | NR | NR | NR | NR | NR | NR | NR | NR | NR | Recovery Road | E-health system, to be used as an adjunct to treatment by pts and clinicians. The system facilitates self management and provides patients with a secure online consultation system, automated patient administered progress monitoring questionnaires with feedback, systematic psychoeducation, and evidence based therapy. | Patient side 12 e0sessions for 12 months, e- progress monitoring and progress report, e-psychological therapy-psychoeducation, e-consultation system, e-medical record, e-diary, pt controlled privacy settings, adherence reminders to complete recovery road sessions and to take medicines. Clinician side Patient progress monitoring outcomes, access to online questionnaires, flags to identify at risk pts, patient brochures, e-consultations, e-medical record. Later on in the study, automated reminders and case management system added. | Computer | progress reports, online consultation, therapy, etc | NR | NR | NR | NR | NR | NR | NR | NR | NR | The author mentions that satisfaction ratings were obtained from pts in public and private sectors using an online questionnaire majority of pts surveyed were satisfied and said that it increased their knowledge of depression and enhanced their relationships with the clinicians All clinicians reported that they were satisfied with the system, 83% reported that it helped the relationship with the patient, 100% reported that it helped the pt to better manage their condition | NR | Mean DSS was severe at session 1 and declined to mild by session 8, a large reduction in depression severity (d (within-subject)= 1.03) 58% of pts had subclinical levels of depressive symptomatology at session 8. | The rate of adherence decline was greater for pts who received only automated reminders than those who received case management. By session 8, adherence for case management was 34% higher than automatic reminders. A Cox regression survival analysis revealed a significant hazard ratio of 2.43 (95% CI=1.01–5.84) for automated reminders relative to case management when controlling for baseline depression severity. Medication adherence at each session ranged from 91% at session 1 to 100% at session 6. | NR | NR | Of the 144 pts referred, 7 withdrew prior to using the system and 23 did not complete the session, data from 2 pts were lost due to technical difficulties | NR | Graphs depicting adherence to recovery road across sessions and depression severity of the patient given.
Robertson | 2005 | NR | Private psychiatric practices, public psychiatry services, and general practice | Homes | Cohort | N= 98 Grp 1 (Standard automated email reminders): 69 Grp 2 (Case management): 29 | NR | 12 months | *Previously or currently satisfying the diagnostic criteria for a major depressive episode *Access to a computer and internet *Willing to use the internet as part of treatment *Willing to provide informed consent *Sufficient cognitive functioning *Proficiency in English *Age ≥ 18 yrs | NR | NR | NR | DEPRESSION | NR | N = 43.87% | Range: 19–64 | NR | NR | NR | NR | NR | NR | NR | NR | NR | Recovery Road | Pts provided with education, progress monitoring, e- consultation, e- diary and online evidence based therapy. | 12 month progressive monitoring and treatment over 12 months, pts received progress monitoring questionnaires, progress graphs and summary progress reports. Additional online features included online evidence based therapy, systematic education, a secure e-consultation system, an e diary and a record of currently and previously prescribed medications. Grp 1: had standard automated e mail reminders for all sessions and in response to non-adherence Grp 2: case management consisting of standard automated e mail reminders for all sessions and email and telephone follow up by a case manager in response to non-adherence | Computer | Progress reports, online consultation, therapy, etc | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | Adherence After first 8 sessions, Grp 1: 55% Grp 2: 84% For both grps adherence tended to decline over time Cox regression survival analysis of non adherence to Recovery Road, controlling for baseline depression, revealed a significant hazard ratio of 2.4 (95% CI, 1.0–5.8), alpha < 0.05 for automated reminders relative to case management | NR | NR | NR | NR | NR
Rodgers A | 2005 | Posters, websites, media articles, email and text messaging mailing lists, in N.Z. | NA | Mobile phone text messaging | RCT | N = 1705 randomized CG: 853 Exp Grp: 852 | NR | 6 months | *Age 16+ *Smoke daily *Ready to quit in 30 days *Able to send/receive text messages *Vodafone owner *Speak English *Informed consent | NR | NR | NR | SMOKING | NR | CG: 41.7% Exp: 41.3% | Mean: 22 | European CG: 63.8% Exp Grp: 62.2% Maori CG: 21% Exp Grp: 20.7% Pacific CG: 3.4% Exp Grp: 3.6% | ($New Zealand): < 15000 CG: 25.2% Exp Grp: 25.9% 15000–30000 CG: 40.9% Exp Grp: 42.7% >30000 CG: 32.1% Exp Grp: 30.1% | NR | NR | Cig/day Mean: 15 both groups | NR | English literate | English | NR | NR | Text messages tailored to preferences, smoking history, barriers to quitting, set around a quit date | Exp Group: 5 per day for 1 week before QD and 4 weeks after, then 3 per week for 26 weeks; 1 free month of text msg for 1 month; Text quit buddy (similar subjects put in touch with each other) CG: text message thanking them and providing contact information every 2 weeks, 1 free month of messaging if completing follow-up. | Mobile phone text messaging | Text messaging, TXT polls, TXT quizzes, TXT buddy | NR | NR | NR | Salivary cotinine on random sample of 100 subjects | NR | NR | NR | NR | NR | NR | NR | Confidence in staying quit: Control 20%, Exp 33% (high confidence at 26 weeks); | 6-week quit rates CG: 13% Exp Grp: 28% Relative risk 2.2 (1.79 to 2.70, p<0.0001) | NR | NR | N = 1705 Data available 6 wks: 1624, 95% (withdrawal = 81) 6 mos: 1265, 74% (withdrawal = 359) | Rate of finger pain Control: 48 (5.6%) Exp Grp: 52 (6.1%) Motor Vehicle Accident Control: 43 (5%) Exp Grp: 38 (4.5%) | NR
Rogers | 2001 | NR | New York Upstate university in Syracuse-Internal medicine outpatient practices | Homes | RCT | N= 121 Usual care: 61 Home service: 60 | May 1999 to April 2000 | NR | *Adults with previous diagnosis of essential hypertension and under evaluation for a change in antihypertensive therapy because of; 1) elevated blood pressure (systolic equal to or more than 140 or diastolic equal to or more than 90 mm Hg) despite current therapy,; 2) undesirable side effects of current antihypertensive medications; 3) office systolic pressure of at least 180 mm Hg or diastolic pressure of at least 110 mm Hg with no current use of antihypertensive medications; *For pts with DM, heart disease, stroke, nephropathy, peripheral arterial disease, or hypertensive retinopathy; *An office systolic BP of at least 130 mm Hg or an office diastolic of at least 85 mm Hg | Pts younger than 18 yrs, pregnant, had secondary hypertension, or did not have the mental or physical capacity to monitor BP at home | NR | NR | HTN | NR | Home service: 43.3% Usual care: 55.7% | Mean (SD); Home service vs. usual care 62.6 (±10) vs. 60.3 (±11.9) | Home service vs. usual care (%) White: 80.7 vs. 91.2 African American:12.3 vs. 7.0 Other: 7 vs. 1.8 | NR | NR | NR | Cigarette smoking (%) Current: 7.3 vs. 16.4 Former: 41.8 s 50.9 Never: 50.9 vs. 32.7 Medical history (%) Cardiovascular disease: 13 vs. 20, Stroke or carotid surgery: 9.3 vs. 12.7 Chronic bronchitis, emphysema or chronic obstructive pulmonary disease:13 vs. 14.6 Diabetes: 22.8 vs. 26.3 Mean body mass index (SD), Kg/m2 31.5 (±7.6) vs. 28.9 (±5.2) Mean total physical activity score 7.32 (±1.27) vs. 7.77 (±1.52) Mean intake of highly saturated fatty foods 15.1 (±7.1) vs. 14.2 (±7.2) Stress (%) Everyday: 15.1 vs. 9.3 Several times a week: 20.8 vs. 16.7 | Private insurance plans or Medicare | NR | NR | NR | Home monitoring service | A home service consisting of automatic transmission of blood pressure data over telephone lines, computerized conversion of the information into report forms, and weekly electronic transmission of the report forms to physicians and patients | Home service: automatic BP recording at home, central processing and electronic reports weekly to pts and physicians; pts instructed to take BP 3 times in the morning before eating or drinking and 3 times in the evening before going to bed, 3 days per week for 8 weeks (could take additional readings if desired) After each reading, device dialed service support center and transmitted data. Results displayed in report form and faxed to the physician, both pt and physician received weekly reports and a summary report at the end.(physicians adjusted medications thru phone calls/office visits or both if required) Usual care: Pts assigned to usual care were treated for hypertension according to guidelines of the joint national committee on prevention, detection and treatment of high blood pressure. | Home monitoring service | Data input, data transmission, data in report format | NR | NR | NR | Mean systolic BP Home service: decreased by 4.9 mm Hg (95% CI: - 1.61 to - 8.12, p=0.005) Usual care: 0.1 mm Hg decrease (95% CI: - 3.43 to 3.17, p>0.2) Mean diastolic BP Home service: decreased by 2 mm Hg (CI: 0.14 to - 4.04, p= 0.072) Usual care: 2.1 mm hg increase (CI: - 0.21 to 4.37, p=0.08) Average mean arterial pressure Home service= decreased 2.8 mm Hg (CI: - 0.59 to - 5.05 mm Hg; p=0.016) Usual care: 1.3 mmHg increase (CI: - 1.01 to 3.67 mm Hg, p>0.2) Statistically significant differences seen in Mean diastolic pressure (difference): 4.1 mm Hg (CI: 0.93 to 7.13 mm Hg, p= 0.012) Mean systolic pressure (difference): 4.8 mm Hg (CI:0.10 to 9.36 mm Hg, p=0.047) Mean arterial pressure (difference): 4.1 mm Hg (CI:0.91 to 7.38, p= 0.013) Pts who received home service were 2.32 times more likely to have improved diastolic BP than Usual care (CI: 1.05 to 5.15) Pts who received home service were 2.52 times more likely to have improved systolic BP than in the usual care group (CI: 1.13 to 5.64) African Americans The mean arterial BP Home service: decreased by 9.6 mm Hg Usual care= increased by 5.25 mm Hg, (p= 0.047) Data suggests that home service may be more effective in obese patients, though interaction term was NS (interaction term: - 2.719 (CI: - 9.334 to 3.896, p= 0.422) mean arterial pressure Home service=decreased by 4.0 mm Hg Usual care: increased by 1.3 mm Hg Among angina pts, mean arterial pressure Usual care grp: increased by 10.0 mm Hg Home service grp: decreased by 6.5 mm Hg (interaction term:13.967, CI: - 2.009 to 29.943, p= 0.090) When data adjusted for age, sex and ethnicity, mean arterial BP Home service: decreased by 3 mm Hg Usual care: increased by 1.4 mm Hg, p= 0.013 When adjusted for age, sex, ethnicity, body mass index, smoking status, intake of high fat food, physical activity and family h/o cardiovascular disease, difference in mean arterial pressure was Home service: - 2.8 mm Hg Usual care: 1.1 mm Hg, p= 0.044. Above target levels Home service: decreased by 6.3% for diastolic and 8.1% for systolic Usual care: increased by 5.6% for diastolic and decreased by 0.5% for systolic. Difference for diastolic pressure: 11.9, CI: 3.6 to 20.1, p = 0.006 Difference for systolic pressure: 7.6, CI: - 0.6 to 15.8. Change in Mean heart rate (NS difference) Home service: - 0.90 beats/min Usual care: - 0.18 beats/min, p> 0.2 | One office visit during the trial Home service: 73.2% Usual care: 60% Significant difference seen in median length of follow up time Home service: 79 days Usual care: 72 days | NR | NR | NR | NR | Pts satisfied with their medical care In both grps, 94% pts said that they agreed with the statement “I feel I am receiving good medical care” 96% of home service and 89% of usual care strongly agreed to the statement that “I feel my doctor had all the information necessary to diagnose or treat me” | NR | NR | NR | NR | NR | Pts identified as possible candidates= 167 cancelled appointment=9, did not keep scheduled appointment=8, found to be ineligible=2 Pts approached by study manager= 148 declined=17 Pts fitted with device=131 declined to continue=2, cannot tolerate device=8 Pts randomly assigned=121 Home service=60 completed=56 Did not complete=4 (withdrew=3, discontinued coz of health problems=1) Usual care= 61 completed trial=55, did not complete=6 (withdrew=4, discontinued coz of health problems=1, lost to follow up=1) | NR | The decrease in BP with home service evident in both men and women, in younger and older patients and in each ethnic group (graph given, values difficult to pinpoint) Medication dose change Home service: 33.3% Usual care: 6.6% p<0.001 Type of antihypertensive medication changed in Home service: 40% Usual care: 27.9% p= 0.159 Significant main outcomes obtained when only pts who participated in the trial for 4 months were included Difference between the two study groups for Mean arterial: p=0.023 Diastolic: p= 0.024 systolic-p= 0.047
Ross SE | 2004 | Outpatient clinic | Specialty clinic | Homes | RCT | N = 107 IVR: 54 CG: 53 | September 2001–September 2002 | 12 mos | *Heart failure patients *Ages 18+ *Speak English *Have used Web browser in the past | Patients who were physicians, nurses or physician assistants | NR | YES: Safety Net Insurance Exp Grp: 19% CG: 19% | CHF | NR | Exp: 80% CG: 74% | Mean Exp Grp: 57 CG: 55 | Caucasian Exp Grp: 92% CG: 88% | <45,000/year Exp Grp: 56% CG: 50% | College Graduate Exp Grp: 53% CG: 44% | NR | Home computer Exp Grp: 96% CG: 94% | Safety Net Insurance Exp Grp: 19% CG: 19% | NR | NR | NR | System Providing Access to Records Online (SPPARO) | Web access to medical record, educational guide, secure messaging | Exp: Access to SPPARO; Control: Usual care | WWW | PHR: clinical notes, lab and test results | NR | Exp: Written user guide provided; Con: None. Offered SPPARO after study was completed | NR | Mortality Exp Grp: 6pts (11%) CG: 6pts (11%) | Utilization during Study Year 2002: % Patients Hospitalized Exp Grp: 20% CG: 23% N Hospitalizations Exp Grp: 22 CG: 21 % going to ER Exp Grp: 20% CG: 13% N ER visits Exp Grp: 20 CG: 8 N Heart Failure Clinic Visits Exp Grp: 324 CG: 325 | NR | NR | SPARRO use highest first 3 months, then averaged 24% of exp. subjects used the program each months N Subjects reviewing record components (cumulative): Notes 41, Labs 37, Radiology 21, Educational guide 27, e-messages 41. Use of e-messaging plus phone messaging Exp Grp: 63 plus 287 CG: 267 phone Total messages first 6 months by group Exp Grp: 150 CG: 88 (p=.05); Total messages second 6 months by group Exp Grp: 109 CG: 103 (p=.66); Message categories Appt schedule: 20% Refill meds: 15% Question on meds: 14% Test results: 12% Feeling ill: 8% Help interpreting tests: 3%. | NR | NR | Satisfaction ratings 0 to 5: How well doctors understand your problems Baseline: 4.5 6 Month IVR vs. CG: 4.4 vs. 4.4 (Diff 0, CI -0.3, 0.2); 12 Month IVR vs. CG: 4.6 vs. 4.2 (Diff +0.4, CI 0.1, 0.6) p=0.02; How well doctors explain what they are doing and why? Baseline: 4.2 6 Month IVR vs. CG: 4.5 - 4.1 (Diff +0.4, CI 0.1, 0.7); 12 Month IVR vs. CG: 4.5 - 4.1(Diff +0.4, CI 0.1, 0.7) p=0.02; | Scored 0 to 100: Baseline 85; 6 month Exp-Control: 88 - 84 (Diff +4, CI -3, 9) 12 Month Exp-Control 91 - 85 (Diff + 6, CI -1, 11) p=0.08 | Medication Adherence (0 to 4): Baseline 3.4; 6 Month Exp-Control: 3.5 - 3.4 (Diff +0.1, CI -0.2, 0.4; 12 Month Exp-Control: 3.6 - 3.4 (Diff +0.2, CI -0.1, 0.6), p=0.15′ General Adherence (0 to 100): Baseline 82: 6 Month Exp-Control: 81 - 78 (Diff +2.3, CI -3.7, 8.3); 12 Month Exp-Cont: 85 - 78 (Diff +6.4, CI 1.8, 10.9), p=0.01 | Scored 0 to 100 Baseline: 56 6 month Exp Grp: 64 CG: 59 (Diff +5, CI -5, 13) 12 month Exp Grp: 64 CG: 62 (Diff +2, CI -7, 11), p=0.63 | NR | NR | None reported; 1 subject disagreed with medical record relating to alcohol use and requested amendment be made. | NR
Rotondi AJ | 2005 | Rehabilitation hospitals | NA | Homes | Cohort | N = 17 | NR | 6 months | TBI patient (traumatic brain injury): *Age 18+ *Was inpatient in rehab hospital *Lives with a female significant other *Speaks English well enough to answer data collection questions FSO (female significant other) of patient: *Age 18 + *Lives as significant other *Speaks English well enough to answer data questions | Excluded if not possessing above requirements | NR | NR | NR | TBI | Patient: 100% FSO: 0% | Mean (Range) Patient: 50.2 (26–67) FSO: 46.4 (24–65) | NR | Family income <$30,000: 61.8% | Less than High school Patient: 45.5% FSO: 22.7% | NA | FSO with no prior computer experience: 23.5% | NR | English literate | NR | NR | WE CARE (web-enabled caregiver access to resources and education) | Home computer with Internet access, support group, education and information libraries | NR | Computer + Internet | Support groups (patient only, caregiver only, both); ask an expert; Q&A Library; Reference library; community resources library and event schedule | Help modules; no stated staff training discussed; technical support available | NR | NR | NA | NA | NR | NR | Evaluation of FSO/Caregiver: Proportion of “hits” to site functions (hits = page view for 1 minute or more) Support group: 68.6% Community services library: 20.1% Q&A library: 5.2% Number of “hits” for 17 users: 838 (±1015) Range: 26–3679 Median: 454. | FSO reports of Ease of Use (1 to 5 point scale, 5=extremely): Overall: 4.1 Compared to other websites: 4.2 Support group: 3.8 Reference library: 3.7 Community resources: 3.5 Ask expert: 3.7 Q&A library: 3.7 Event calendar 3.6. FSO report of Value (1 to 5 scale, 5=extremely valuable): Overall 3.9 Compared to other sites: 3.9 Support group: 3.8 Reference library: 3.4 Community resources: 3.3 Ask expert: 3.4 Q&A library: 3.5 Events calendar: 2.5. | FSO [underlined: reaction] to site: Helpful: 75% extremely, 18.8% very Satisfying: 43.8% extremely, 31.3% very Wonderful: 100% extremely Dull: 0% extremely, 0% very, 6.3% moderately PSO [underlined: Emotions] while using site: Supportive: 7.7% extremely, 76.9% very Motivation: 7.7% extremely, 38.5% very, 15.4% moderately Understanding: 26.7% extremely, 33.3% very, 26.7% moderately | NR | NR | NR | NR | Categories (frequencies) of Support Messages by FSO Self-disclosure: 32.3% Provide emotional support: 29.1% Request information or clarification: 6.8% Provide advice/offer solution: 6.2% Interpretation: 5.2% Request for feedback: 5.1% Agreement: 4.4% Shared norms/group process: 4.1% Validation/normalization: 3.3% Provide information: 2.3% Identify with group: 1.1% Negative/flaming: 0%. | 4 dropped out before computer provided 2 received computer but had no interest in the intervention. | NR | NR
Ruland | 2003 | Cancer patients attending outpatient department | Outpatient clinic | Outpatient clinic | Randomized trial (pilot study) | N=52 Grp 1 (IG): 27 Grp 2 (IG); 25 | 2 mos | Same Day | *Age ≥21 yrs *Able to read, write and speak English *No cognitive impairment *Able to provide informed consent *Not too fatigued *Participation approved by patient's physician | New patients coming for their first visit | NR | NR | CANCER | NR | N = 61% | Mean (SD) 56.3 (+11.3) Range: 23–77 | NR | NR | Mean years (SD): 12.8 (±2.38) Range: 4–20 | NR | Clinician sample N=14 Assigned to Grp 1: 9 Assigned to Grp 2: 5 Clinicians were seeing mean of 3.5 pts (±2.8) Range: 1–9 | NR | NR | English | NR | CHOICEs | Comprehensive patient assessment tool for cancer specific symptoms, functional problems, and preferences along physical, psychosocial, emotional and spiritual dimensions SDM/ care planning component that highlights for clinicians which symptoms patients are experiencing, severity, degree of bother and importance to the patient | Grp 1: study explained and informed consent taken, use of touch screen computer explained pts completed CHOICEs assessment on the computer with or without help of interview assistant, pts completed the ease of use questionnaire assessment summaries printed and given to pts and clinicians in subsequent consultations Grp 2: same as above except assessment summaries were neither printed nor given to patient or clinician at any time | Computer | Questions, CHOICEs assessment | NR | Pts were explained the use of the touch screen computer | NR | Pts Mean score for perceived overall health (SD): 6.17 (±2.5) Range: 0–10 Mean selected symptoms (SD): 15.10 (±13.96) Range: 1–50 Number of reported symptoms in IG and CG: No significant difference Out of 16 problem categories in CHOICEs Energy problems with associated symptoms: 63.5% Pain: 53.8% Worries/concern: 50.0% Sleep/rest and mood/feelings: 46.2% Grp differences in congruence b/w Pt reported symptoms and those addressed in the pt consultation Congruence Mean (SD) Grp1 vs. Grp 2 2.84 (±2.98) vs. 7.63 (±7.37) t= 3.11, df- 50 (1), p < 0.01 Importance weighted congruence Mean (SD) Grp1 vs. Grp 2 12.8 (±15.7) vs. 33.0 (±33.7), t= 2.84, df- 50 (1), p< 0.01 | NR | NR | NR | Time reqd median of 9 mins (±10.35) Range: 0.5 to 49 mins) 25% of sample used 5 mins or less | Completed assessment on touch pad comp without assistance: 80% Had assistance (reasons- too weak, had disabilities, out of convenience): 20% Reliability of instrument: Cronbach's alpha 0.98 Personal comments of pts added: not reported here Ease of use correlated with previous comp experience: (r=0.42, p<0.01) | No significant grp differences in pt satisfaction t= 0.75 p=0.45 (pt satisfaction scores skewed) | NR | NR | NR | Perceived HRQoL: 6.59 (±2.44) Range: 0–10 | NR | 73 approached; 14 did not wish to participate; 59 consented; 3 withdrew as received bad news and did not wish to complete questionnaire; 2 were not well; 2 did not like computers | NR | Number of symptoms reported by pts having influence on number addressed in the consult given- ANCOVA results not reported here
Runge | 2006 | Volunteer | General Practitioner (GP) offices and outpatient facilities | 36 study centers (includes GP offices and outpatient facilities) | Nonrandomized between group | N = 358 | 12 months | None | *Ages 8–16 years *Presence of confirmed asthma diagnosis for at least 1 year *No other asthma program participation prior to study entry *Sufficient knowledge of German language was assumed *Obtain informed consent | Outside age range, no asthma, prior participation in an asthma program, not speaking German, no informed consent | NR | NR | ASTHMA | NR | CG: 79.2% SPMP: 54.7% SPMP + IEP: 65.9% | Ages 8–16 Mean Ages: CG = 11.5 (±)2.9 SPMP = 11.1 (±)2.4 SPMP + IEP: 11.0 (±)2.2 | German | NR | NR | NR | NR | Cost-benefit ratio for each intervention strategy was analyzed from the perspective of health insurance (German) | NR | German | Believe in the positive impact of patient education, but unhappy that only less than 1% of all children in Germany are instructed in a systematic manner per year | Standardized Patient Management Program and Internet based education program (asthmamax.de) | SPMP: educational sessions about asthma knowledge and asthma self-management skill, IEP: internet educational module with asthma-related quizzes and interactive adventure games incorporating asthma-related situations, schedule chats with asthma experts, on-line peak flow protocol, chat rooms | CG (n=48): baseline clinical visit, second clinical visit after 6mos SPMP (n=86): baseline clinical visit, second clinical visit after 6mos, final clinical visit after 12mos + educational instruction SPMP + IEP (n=44): baseline clinical visit, second clinical visit after 6mos, final clinical visit after 12mos + educational instruction + internet-education program access | Classroom, Internet | Education and self-management skills, also cost-benefit analysis | NR | NR | NR | Lung Function Tests CG: Baseline PEF = 324+98 First Visit = 341+110* SPMP: Baseline PEF = 347 + 94 First Visit = 366+101* Second Visit = 376 + 97* SPMP + IEP: Baseline PEF = 340 + 86* First Visit = 363 + 89* Second Visit = 368 + 92* *P>0.05 v. baseline visit (Wilcoxon test) | Clinic visits at 0, 6, and 12 month periods, patient outcomes under usual care was also noted, scheduled chats with asthma experts (IEP only) | *See actual paper for Data (not relevant to list since cost is in Euros and based on universal healthcare) | NR | Average 2hours/mo | Peak flow protocol section, patient chat room, and asthma adventure game were the most used of the site | NR | NR | See Quality of Life ratings below | NR | KINDL Questionnaire: 75.5+11.78 CG: T_0_ = 76.5 T_1_ = 74.9 SPMP: T_0_ = 75.0 T_1_ = 77.2 T_2_ = 79.3 SPMP + IEP: T_0_ = 75.3 T_1_ = 77.3 T_2_ = 80.5 | Regular physician check-ups, scheduled chats with asthma experts (IEP only), chat rooms with peers (IEP only), teacher-classmates (SPMP and/or IEP only) | N = 124 (34.6%) Relocation of patients: 6 Withdrawal of Caregiver consent: 6 Nonattendance of scheduled follow-up visits: 11 No returning of mail questionnaires: 41 Relocation of personnel in two study center: 41 Reasons not documented: 41 | NR | *Outcomes not abstracted: cost-benefit ratio due to reasons listed below
Safren | 2002 | NR | NR | Home/with patient | Cohort | NR | 3 months | NR | NR | NR | NR | NR | HIV/AIDS | NR | NR | NR | American | NR | NR | NR | None | NR | NR | English | NR | MediMom | Pager system: a clinician or investigator input a patient's medication regimen into an Internet computer program; the patient carried a beeper that had a display window, and when it was time for the patient to prepare or take a pill, the beeper notified the patient with instructions | IVR Grp Control Grp | Pager | Medication reminder | NR | NR | NR | NR | NR | NR | NR | Adherence IVR Grp 2 weeks: 70% 12 weeks: 64% CG 2 weeks: 56% 12 weeks: 52% | Reported that younger employees tended to use the e-mail as a communication tool for health counseling more than older employees, and there are different levels of skill and acceptability for e-mail among employees in administrative and manufacturing divisions | NR | NR | NR | NR | NR | NR | NR | NR | Adherence was assessed through a pill bottle system that recorded each time a patient opened the bottle to take out a pill. Could underreport if patient took out more pills, like to go on vacation
Sciamanna | 2004 | Public health clinic waiting room | NR | Computer in clinic | Cohort study | N = 150 | October 2001–February 2002 | NA | *1 provider at 10 clinic sites *Patient with same day visit with study provider | Non-English speaking | NR | YES: all | 95 (63.3%) | NR | N = 32.43% | Range ≤25: 22 pts (14.7%) 25–34: 24 pts (16.0%) 35–44: 31 pts (20.7%) 45–54: 32 pts (21.3%) ≥55: 41 pts (27.3%) | Caucasian: 123 pts (83.1%) Black: 6 pts (4.1%) Hispanic: 17 pts (11.4%) Other: 2 pts (1.4%) | NR | <HS: 32 (21.3%) HS: 47 (31.3%) HS+: 71 (47.4%) | NR | Exercise <150 min/wk: 51% | NR | NR | English | NR | NR | Computer assessment with tailored printed feedback | NA | Computer | Computerized assessment on smoking and physical activity, 4–5 page report tailored feedback, 1-page provider report | NR | None, research associate available for help if needed | 31.3% patients used Internet | NA | NA | NR | NR | NR | Asked for help using computer: 12% Felt computer easy to use: 81.1% | NR | Satisfaction with provider visit significantly related to having a chronic condition, being a nonsmoker, and having a provider who reviewed the report with the patient | NR | NR | NR | NR | NR | Patients: 266/208/150 | 24.8% patients had privacy concerns using computer
Sciamanna | 2005 | Secure website | NR | WWW | Randomized Group | N = 121 Grp 1: 57 Grp 2: 64 | NR | NA | *List of people with self-reported OA from a marketing organization and had knee pain 3+ months, saw doctor for knee pain, and told diagnosis of osteoarthritis | NR | NR | NR | OSTEOARTHRITIS OF THE KNEE | NR | N = 23.1% | Mean: 47.8 | Caucasian: 86.8% Black: 6.6% Native American: 2.5% Hispanic: 3.3% Other: 5% | NR | ≥College: 25.6% | NR | NR | NR | NR | NR | NR | myexpertdoctor.com | Computer assessment with tailored feedback about OA and OA care | Group 1: satisfaction with OA care before using website; Grp 2: satisfaction with OA care after using website | Secure website | Computer assessment on OA, satisfaction with care; computer personalized feedback about OA quality of care and treatment recommendations | NR | NR | Uses Internet for health at least several times per month: 65.5% | NA | NA | NR | NA | NR | Easy to use: 97.5% | Website ratings: 23.1% excellent, 52.9% very good, 24% good; Website could: *help get better care: 77.7% *help manage OA: 86.8% *help talk to doctor: 81.8% *better understand OA: 90.1% | Overall satisfaction with medical care: Grp 1: 67.9% Grp 2: 69.5% No difference in satisfaction in technical quality, physician manner, doctor-patient communication, or time spent with doctor | NR | NR | NR | NR | NR | NR | NR
Shapiro | 2007 | NR | NR | Homes | Randomized wait-list control | N= 66 Grp 1 (CBT): 22 Grp 2 (CD-ROM): 22 Grp 3: (Waiting list [WL]): 22 | NR | 2 month | *Age range between 18–60 *Current diagnosis of DSM IV BED based on the SCID broadened to include individuals with sub threshold BED who acknowledged engaging in at least two objective binge eating episodes/month *BMI equal to or more than 27 Kg/m^2^ ^*R^egular access to IBM compatible computer. | Current AN or BN; current severe depression or active suicidal intent; any developmental or learning disorder or cognitive impairment contraindicating CBT or the effective use of a computer and currently taking medication for the treatment of obesity. Individuals currently taking psychoactive medication were not excluded provided their medication dose was stable and their eating behaviors had remained stable during the course of medication treatment. | NR | NR | EATING DISORDER | NR | CBT: 9.09% CD-ROM: 9.09% WL: 4.55% Total: 7.58% | Mean (SD) CBT: 39.14 (±11.43) CD-ROM: 40.41 (±10.61) WL: 39.09 (±13.48) Total: 39.55 (±11.73) | Black (not Hispanic) CBT: 31.82% CD-ROM: 27.27% WL: 22.73% Total: 27.27% White (not Hispanic) CBT: 68.18% CD-ROM: 63.64% WL: 77.27% Total: 69.7-% Asian CBT: 0 CD-ROM: 4.55% WL: 0 Total: 1.52% Other CBT: 0 CD-ROM: 4.55% WL: 0 Total: 1.52% | NR | NR | NR | Never married CBT: 36.36% CD-ROM: 33.33% WL: 22.73% Total: 30.77% Married CBT: 31.82% CD-ROM: 28.57% WL: 27.27% Total: 29.23% Monogamous relationship and living with partner CBT: 31.82% CD-ROM: 38.10% WL: 50% Total: 40% BMI Mean (SD) CBT: 37.72 (±9.45) CD-ROM: 39.63 (±7.88) WL: 34.70 (±6.61) Total: 37.35 (±8.20) No BED CBT: 28.57% CD-ROM: 28.57% WL: 33.33% Total: 30.16% BED CBT: 71.43%: CD-ROM: 71.43% WL: 66.67% Total: 69.84% | NR | NR | NR | NR | CD-ROM based cognitive behavioral treatment | CD-ROM based cognitive behavioral treatment for binge eating disorder focusing on balanced nutrition, regular exercise, psychoeducation, individualized interactive CBT exercises, tracking system applicable to a broad range of adult men and women from all races and background. | Grp 1= Group CBT; 10 weeks of group treatment for weekly 90 min sessions in small grps. Facilitated by PhD level psychologist and consisted of psychoeducation on healthy nutrition, daily food and behavior diaries, identifying thoughts, feelings and behaviors related to binge eating episodes, challenging and restructuring thoughts and techniques for avoiding unhealthy behavior. Grp 2= CD-ROM based cognitive behavioral program for treatment of obesity that focuses on balanced nutrition, regular exercise, psychoeducation, basic concepts, techniques and examples of CBT, individualized interactive CBT exercises, helpful guidelines for slip control and relapse prevention, tracking system to monitor utilization and applicable to a broad range of adult men and women from all races and background. (1 brief contact with the RA to assess technical aspects of the program) Grp 3= Pts were told that they would be contacted in 10 weeks for reassessment and would then be offered a choice to receive Group CBT or CD-Room based treatment. | Computer | individualized interactive cognitive behavior exercises, education | NR | NR | NR | NR | NR | NR | NR | At the follow up, 66.7% of those in the CD-Rom condition reported that they had used the same at least once or twice after completing the program | NR | NR | NR | NR | At baseline, individuals in the CD-ROM reported more binge eating days and fast food consumption and also had a higher weight and BMI than those in the WL condition. At post treatment, no significant difference between the groups. In terms of abstinence, in CD Room grp, 13.3% and 12.5% were binge free at post treatment and follow up respectively. In the group CBT, 7.7% and 22.2% were binge free at post treatment and follow p respectively. In the WL, no pt was binge free at post treatment. Table 2 gives values of outcome variables summarized above | NR | NR | Drop out rates prior to the end of 10 weeks, CD-ROM= 31.5%, Group CBT= 40.9%, WL= 9% Overall difference was statistically significant(p<0.05) with significantly more dropouts in the group condition than the WL (p<0.03) and no difference between either CD-ROM and group or CD-ROM and WL. | NR | Changes in binge days over time (CDROM vs. Group CBT vs. WL) Baseline LS means (SD) 2.85 (0.21) vs. 2.76(0.23) vs. 2.77 (0.18) Post treatment LS means (SD) 2.42 (0.18) vs. 2.12(0.18) vs. 2.71(0.13) Two month follow up LS means (SD) 2.00 (0.30) vs. 1.49(0.31) vs. 2.65(0.18) No pair wise p values were significant but the interaction term for treatment group by visit was significant(p<0.04) 75% of those who completed the WL condition chose to receive the CD-ROM over group treatment
Shaw | 2007 | (5) NCI's Cancer Information Service, hospitals, clinics, public health departments, and Medicaid program. | NR | Homes | RCT | N = 231 Exp (HCl): 18 CG (RC): 17 | Detroit: June 2001 – April 2003 Wisconsin: May 2001 – April 2003 | 4 months | *Poverty Level <= 250% of the federal poverty level *Within 1 year of diagnosis or had metastatic breast cancer *Not homeless *Able to read and understand an informed consent letter | Homeless | NR | YES: Low-Income: <=250% of the federal poverty level | METASTIC BREAST CANCER | NR | N = 0% | Mean (SD): 51.58 (±11.81) | N = 231 Caucasian: 144 pts (62.3%) African-American: 83pts (35.9%) Other: (1.7%) | NR | N = 231 Some junior high: 2pts (0.9%) Some high school: 24pts (10.4%) High school degree: 72pts (31.2%) Some college: 69pts (29.9%) Associate or technical degree: 28pts (12.1%) Bachelor's degree: 28pts (12.1%) Graduate degree: 8pts (3.5%) | Detroit cohort: Unknown Wisconsin cohort: Rural | On average, women had been diagnosed 4 months before the start of the DDPP study with more than two-thirds of them being in the relatively early stages of cancer. | NR | Must be able to read and understand an informed consent letter | NR | NR | CHESS | CHESS: a browser which automatically collects data on an individual keystroke level as participants used the system. This capability enabled us to track each user's code name, data, time spent and URL of every Web page requested. The key variables of interest are four measures of CHESS service use: information, discussion group, ask an expert, and interactive service. | Group 1: 231 subjects all received same treatment. After submitting their pretest, all study participants were loaned a computer and given Internet access for 4 months. They also received personal training to learn how to use the computer and the Internet, but the majority of time was spent on learning how to use CHESS. Interactive Services, one of four services offered by CHESS; There may be prompts from the computer, but the computer is not, for the most part, guiding the user. | Home computer + Internet | To serve as platform for study intervention (CHESS) and | NR | They also received personal training to learn how to use the computer and the Internet, but the majority of time was spent on learning how to use CHESS. | NR | NR | NR | NR | In the current study, the change in information competence from the pre to post-test was statistically significant Pre- test Mean: 2.37 (±0.69) Post-test Mean: 2.83 (±0.64), \|t\| = 10.21, P < 0.001) Effect size calculated via Cohen's d = 0.69 Pre-test reliability a = 0.75 Post-test reliability a = 0.79 As expected, pre-test level of the dependent variable had a strong, significant relationship with the dependent variable (health information competence) (b = 0.455 or 463, P < 0.01) Interaction between information and interactive services was significant (b = 0.206, P < 0.01). Interaction between information services and discussion group use (b = 0.163, P < 0.01) was also significant The first and second interaction effect blocks explained additional significant variances (2.1%) and(2.6%), respectively, in information competence | Key variables of interest are four measures of CHESS service use: Information Mean: 35.46 (±56.78) Median: 16.89 Range: 475.4 Discussion group Mean: 506.18 (±1369.35) Median = 62.59 Range: 12743.8 Ask an expert Mean: 27.96 (±51.64) Median: 6.46 Range: 432.0 Interactive service Mean: 27.85 (±52.86) Median: 9.88 Range: 500.7 | NR | NR | NR | NR | NR | NR | NR | 286 recruited 231 (81%) completed both pre-test and post-test surveys. Withdrawal: 55, or 19%. | NR | NR
Shegog | 2001 | 6 clinics and 7 schools in a large urban area | Houston, TX | Clinic | RCT | N=76 | 1 year | NR | *Been diagnosed as having asthma by their health care provider *Age 7–13 | Did not have a diagnosis of asthma or was outside of the age range | NR | NR | YES: ASTHMA | NR | 65.00% | Mean: 10.7 Range: 8–13 | White non-Hispanic: 47.9% African American: 40.8% Hispanic: 7.0% Other: 2.8% Asian: 2.6% | NR | School Grades As&Bs: 73.2% Bs&Cs: 23.9% Cs&Ds: 2.8% | Children recruited from schools and clinics in a “large urban area” | Asthma Severity Low: 15.5% Mild: 38.0% Moderate: 35.2% Severe: 11.3% | NR | NR | NR | NR | Watch, Discover, Think and Act (WDTA) | Theory-based application of CD-ROM educational technology for pediatric asthma self-management education | IVR: 38 CG: 33 | Computer game | To provide education about asthma to children | NR | NR | NR | NR | NR | NR | Knowledge questionnaire Pretest Mean (SD) CG: 15.7 (+5.8) IVR: 18.6 (+5.1) Posttest Mean (SD) CG: 17.8 (±6.3) IVR: 21.1 (±5.4) Posttest Scores Self-regulation CG: 0.06 (±0.3) IVR: 3.3 (±1.3) Prevention CG: 1.8 (±1.0) IVR: 2.7 (±1.1) Treatment CG: 1.5 (±0.8) IVR: 2.7 (±1.4) | NR | NR | NR | NR | Pretest CG: 51.6 (±9.7) IVR: 53.4 (±9.7) Posttest CG: 51.5 (±10.7) IVR: 56.5 (±9.8) | NR | NR | NR | Lack of availability for follow-up: 4 Refusal to participate further: 1 | NR | NR
Skeels | 2006 | HIV clinic and Community based HIV organization | Outpatient clinics | Clinic | Cohort | N= 30 | NR | 1 week | NR | NR | NR | NR | HIV | NR | NR | NR | NR | NR | Middle school /High school: 10 pts Some college: 15 pts College graduate: 4 pts ≥Masters Degree: 1 pt | NR | Used computer few times or never: 7 pts Experienced users: 11 pts | NR | NR | NR | NR | Computer assessment and treatment education for HIV+ (CARE+) | Goal - to improve ART adherence and to lower risk of secondary infections Pts answer tailored risk assessment questions about social support, sexual behavior etc., CARE+ provides personalized feedback (identifies areas of trouble and areas where they are doing well), skill building videos, risk reduction plan focused on ART adherence or reducing risk of secondary infections. Used in clinic prior to meeting provider, printout of plan received to keep or discuss with provider. | Pts explained on how to navigate CARE+ Questionnaire to collect demographic and background info, use of CARE+ observed. Semi structured interview to identify usability issues and assess views on computer counseling | Tablet PC | Tailored assessment, personalized plan | NR | Explained as to how to navigate CARE+ | NR | NR | NR | NR | NR | NR | All 30 completed the CARE+, 5 had experience using Tablet PC before Many participants had positive comments- not listed here Three main issues identified by observation and interview *Seeing the screen (eyesight impairment due to HIV medication, lighting probs) *Target acquisition (difficulty with selecting buttons in CARE+ screens) *Difficulties tapping More details (pts responses) given but not listed here | NR | NR | NR | NR | NR | NR | NR | NR | Attitudes toward CARE Issues discussed in the interview Honesty, judgment, embarrassment, compassion, trust, privacy, accessibility convenience, sympathy, importance of human dialogue and interaction miscommunications, preference for computer counseling or person to person counseling. (Detailed responses of pts given but not listed here) The author also mentions that the follow up session was used for test-retest reliability of CARE+ questionnaire (no details given)
Smith | 2000 | Rural-at least 25 miles away from 6 major cities of Montana | Certified diabetes educator centers | Homes | RCT | N=30 Computer: 15 Non-computer: 15 | NR | 10 months | *Female *Diabetes- type 1 or 2 *Ages 35–60 yrs *Able to read and write English *Possess the sight and dexterity to use a computer (not necessarily be computer literate) *Have a telephone in their home *Live at least 25 miles out of 6 major cities in Montana | NR | NR | YES: rural | DIABETES | NR | N = 0% | Mean: 46.7 | NR | NR | NR | Rural: at least 25 miles away from 6 major cities of Montana | Married: 80% Employees: 60% | NR | NR | NR | NR | Women to women diabetes project | 5 month computer intervention involved installing comp/software, providing each women with a health info notebook on general health and specific diabetes info. 4 components; (1) Conversation area- pts encouraged to converse with each other about anything, comments open and available, monitored by CDE, CDE did not actively participate unless invited by pts or to redirect inappropriate participation; (2) Mailbox- pts speak privately with each other or to the nurse monitor.; (3) Health chat area- structured, electronic classroom, open for all, questions specific to dealing with diabetes encouraged and articles from health info notebook discussed, active role by CDE; (4) Recourse rack- bulletin board on which project team posted items of interest to people with diabetes, e.g.- dates and time of ADA-MT conference. read only feature and pts could not post anything here. | Computer Group: all of the above Non computer group: hard copy of all materials computer group was given (health info notebook and computer-generated info) | Computer | Chats, questions, post messages, mailbox | NR | Computer group trained in the use of software and how to log in and connect to the system At the first visit, confidentiality and support group participation were reviewed and protocol of the project explained A toll free line available to contact the study team (both groups) | NR | NR | NR | NR | NR | Mean minutes logged on per month Month 1: 129 Month 2: 68 Month 3: 78 Month 4: 44 Month 5: 37 Conversation area: each woman used 111 times over the course of 5 months Mailbox: each woman used around 40 times over the course of 5 months Health chat: accessed 38 times by each | NR | NR | NR | Psychosocial adjustment to illness scale Computer group vs. non computer group 77.79 vs. 80.24 | NR | Raw mean scores Quality of life Computer group: 17.1755 Non-Computer group: 17.9014 | Raw mean scores Personal resource questionnaire Computer Grp: 121.76 Non-Computer Grp: 128.53 | NR | NR | Supportive/informational conversation given but not reported here Importance of components of the intervention as perceived by pts given, not listed here Attitudes of the pts toward the intervention describes (qualitative responses recorded) not listed here
Southard | 2003 | Hospital and community physician referral | Cardiac rehabilitation centers | Homes | RCT | N = 104 CG: 51 Exp Grp: 53 | NR | 6 months | *Coronary heart disease *CHF *Possessing both | No a priori criteria reported; excluded subjects including a relative of a subject, lack of MD referral, failure to complete blood tests | Yes: Mean age = 62 | NR | CARDIOVASCULAR DISEASE | NR | N = 75% | Mean Exp Grp: 61.8 Usual Care: 62.8 | Not Caucasian Exp Grp: 1.9% UC: 3.9% | Exp Grp <20000: 1.34% 20000–40000: 19.2% 40000–60000: 13.5% 60000–80000: 17.3% 80000–100000: 9.6% >100000: 5.8% Usual Care <20000: 5.9% 20000–40000: 25.5% 40000–60000: 17.6% 60000–80000: 17.3% 80000–100000: 9.6% >100000: 7.8% | Exp Grp HS: 26.4% Trade school: 28.3% >HS: 43.4% CG HS: 25.5% Trade school: 15.7% >HS: 51% | NR | NR | NR | NR | NR | NR | Online case management, tailored feedback, support group | Online case management (once/week for 30 minutes) | NR | Website | Self-monitoring, secure messaging with case manager and dietician, education modules with graphic feedback, online group | NR | NR | Ad hoc telephone | Mean values, baseline and follow-up Weight CG: 196.2 to 196.7 Exp Grp: 202.8 to 199.2 (p=.003) BMI CG: 29.2 to 29.3 Exp Grp: 30.9 to 30.3 (p=.003) Systolic BP CG: 130.9 to 128.8 Exp Grp: 131.7 to 129.4 (p=ns) Diastolic BP CG: 72.1 to 71.8 Exp Grp: 74.4 to 72.5 (p=ns) Cholesterol CG: 181.8 to 175.1 Exp Grp: 183.3 to 178.1 (ns) LDL CG: 109.3 to 107.9 Exp Grp: 108.4 to 103.4 (ns) HDL CG: 41.5 to 39.7 Exp Grp: 39.5 to 37.7 (ns) | Major cardiovascular event rate CG: 15.7% Exp Grp: 4.1% (Fisher's p = .053) | Estimates for major CVD events: CG: $104,684 Exp Grp: $31,110 | NR | 1-week time analysis with 31 experimental subjects: estimated 10.8 hours of health professional time per 6-month period | NR | NR | NR | NR | Minutes of exercise (self-report) per week, baseline and follow-up: CG: 142.4 to 165 Exp Grp: 150.2 to 208.4 (NS) | NR | NR | NR | NR | NR
Stinson | 2006 | Purposive sample | Rheumatology clinic, university-affiliated pediatric tertiary care center | Homes | Cohort | N = 10 Phase I: 10 Phase II: 10 | 15 days | None | *Between ages 9–18 *Diagnosed with JIA by rheumatologist *Had experienced pain over past 24 hours *Able to speak and read English | Having known major cognitive or psychiatric disorders that might interfere with ability complete self-reported daily pain ratings, having other known major medical disorders (i.e. Crohn's disease) that would be a source of chronic pain, known severe vision problems that would interfere with ability to see e-Ouch screen, known hand deformities that would prevent use of the electronic diary | NR | NR | Juvenile Idiopathic Arthritis [JIA] | NR | Phase I: 20% Phase II: 20% | Mean Age: 13.55 (±)2.68 Phase I: 13.6 (±)2.8 Phase II: 13.5 (±)2.72 | NR | NR | School Grade Phase I: Public School (n = 6): 60% HS (n=4): 40% Phase II: Public School (n=6): 60% HS (n=4): 40% | NR | NR | NR | NR | NR | Believe that assessment in the form of documentation is the best way to tackle managing pain and effectiveness of therapies | e-Ouch Electronic Pain Diary | Obtains 3 daily pain ratings (upon waking, after school, before bed), uses scroll bar slide (No Pain—Very Much Pain) as well as a slide with front and back view of human body asking viewer to indicate “parts of the body picture” where they hurt at that moment | Phase I: usual care + e-Ouch Pain Diary Phase II: usual care + e-Ouch Pain Diary | Internet, e-Ouch Pain Diary is a PDA | Keep track of severity of pain, medication used, area of pain, and other factors inhibited by pain (social, academic, etc.) | NR | Initial introduction to pain diary, otherwise NR | NR | *See table below | NR | NR | NR | NR | Quotes: “very easy to learn” “very easy to use” | Quotes: “really cool” “better than just getting a book full of blank paper and writing down about your pain each day” | NR | NR | NR | *See table below | NR | NR | NR | Various changes to the software to improve usability and make the program more efficient with fewer errors *Study also includes table that lists the types of arthritis the pts were experiencing
Strecher | 2006 | NR | NR | Homes | RCT | N= 3971 CQ Plan: 1991 CG: 1980 | NR | 12 months | *Target quit date that was within 7 days of the enrollment date *Provided a valid e-mail address and had internet access for the duration of the study *Were attempting to quit smoking cigarettes (i.e. not smokeless tobacco) *Had been smoking more than 10 cigarettes /day *Had purchased NiQuitin CQ 21 mg *Agreed to be contacted for follow up e-mail and web based questionnaires at 6 and 12 weeks *Age ≥ 18 yrs | NR | NR | NR | SMOKING | NR | N = 43.5% Grp 1 vs. Grp 2: 57.9% vs. 50% | Mean (SD): 36.9 (±10.2) >40 yrs Grp 1: 58.4 Grp 2: 48.6 ≤40 Grp 1: 50.4 Grp 2: 40.3 | NR | NR | NR | NR | Subjects smoked an average of 23.5 cigarettes/day (±8.2) Pts had smoked cigarettes for an average of 20.1 yrs (±10.3) Subjects who smoked their first cigarette of the day within 30 mins of waking: 88.4% | NR | NR | NR | NR | CQ PLAN (committed quitters stop smoking plan) | Tailored web based smoking cessation materials | Grp 1: web based committed quitters stop smoking plan- Info collected in the enrollment questionnaire used to tailor CQ PLAN materials including demographics, smoking history, motives for quitting, expected difficulties quitting, ans situations that were expected to present challenges. Pts also identified a supportive person that would receive an email with tailored advice for supporting the subject. Initial web based cessation guide, three sequential tailored newsletters delivered via the web, and behavioral support messages delivered via internet for a 10 week period. Grp 2: web based control condition- web based materials had a graphic design and navigational structure very similar to the CQ PLAN, cognitive behavioral concepts and instructions on the product use similar to the CQ PLAN. The main differences were, this grp did not receive tailored materials, the three follow up newsletters and the opportunity to identify a supportive person | Computer | Tailored web based smoking cessation materials, e mail messages, newsletters etc | NR | NR | NR | Tobacco related illness Yes: Grp 1 vs. Grp 2 55.6 vs. 38.2, OR (95%CI)= 2.07 (1.42–3.00), p<0.001 No: Grp 1 vs. Grp 2 51.9 vs. 45.3, OR(95% CI)=1.30 (1.02–1.66), p<0.05 Interaction OR (95% CI)=1.26(1.01–1.57), p<0.05 | NR | NR | NR | NR | NR | NR | NR | Self efficacy, Low ; Grp 1 vs. Grp 2; 49.9 vs. 42.2, OR (95%CI)=1.36 (1.01–1.85), p<0.05 High; Grp 1 vs. Grp 2;56.8 vs. 44.8, OR(95% CI)= 1.63 (1.22–2.19), p<0.001 Interaction OR (95% CI)= 1.09 (0.89–1.35), Motivation to quit high; Grp 1 vs. Grp 2; 54.6 vs. 44.8, OR (95%CI)= 1.49(1.19–1.93), p<0.001 Low; Grp 1 vs. Grp 2; 48.4 vs. 38.9, OR(95% CI)= 1.47 (1.00–2.20), p<0.10 Interaction OR (95% CI)= 1.01 (0.80–1.27) Weight Concern Yes; Grp 1 vs. Grp 2; 55.8 vs. 41.8, OR (95%CI)= 1.78 (1.18–2.17), p<0.01 No; Grp 1 vs. Grp 2; 52.2 vs. 43.7, OR(95% CI)= 1.41 (1.12–1.79), p<0.01 interaction OR (95% CI)= 1.12 (0.89–1.43) Psychosocial stress high; grp 1 vs. grp 2; 49.2 vs. 41.1, OR (95%CI)= 1.39 (1.05–1.83), p<0.05 Low; grp 1 vs. grp 2; 58.3 vs. 45.5, OR(95% CI)= 1.68 (1.23–2.30), p<0.01 interaction OR (95% CI)= 0.91 (0.74–1.12) | No of cigarettes smoked More than 20; Grp 1 vs. Grp 2; vs., OR (95%CI)=, p<0.001 ≤20; Grp 1 vs. Grp 2; vs., OR(95% CI)=, p<0.05 Interaction OR (95% CI)=, p<0.05 First cigarette of the day ≤5 mins; Grp 1 vs. Grp 2; 51.8 vs. 45, OR (95%CI)=1.32(0.96–1.82), p<0.1 No; Grp 1 vs. Grp 2; 53.9 vs. 41.7, OR(95% CI) =1.63 (1.25–2.12),p<0.001 Interaction OR (95% CI)= 1.11 (0.90–1.36) | NR | NR | Total= 3971 CQ Plan: 232 never logged on Control: 238 never logged on Out of the 3501 who logged on, 31 withdrew CQ PLAN: 15 Control: 16 A total of 3470 received the 6 week FU survey 1850 responded to this survey Between the 6 an 12 week survey, 15 more withdrew CQPLAN: 8 Control: 7 This left 3455 pts, out of which 1491 responded to the 12 week survey | NR | Details about Non smoking children and adult smokers given, not listed here Figure depicting mediation pathway of tailored treatment, perceived relevance and smoking cessation given
Stuart | 2003 | 30 primary care practices | Primary care practices | Home | Randomzied three group | N=647 | 1 year | NR | *Age ≥18 yrs *English literate *Not currently taking an antidepressant medication *Newly prescribed an antidepressant medication by their primary care provider *Access to a touch-tone telephone *Willingness to participate in the study | Any criteria against the Inclusion criteria | NR | NR | DEPRESSION | NR | NR | NR | American | NR | NR | NR | None | NR | English literate | English | NR | Interactive Voice Response Intervention | Automated telephone answering/reminding system | Grp 1: Education-treatment team education and patient self-care education Grp 2: Education and Call: education listed above + 1 office nurse telephone call within 2 days of the visit when the antidepressant medication was prescribed Grp 3: Education + Call + IVR: education and call listed above + IVR program lasting for 3 months | Telephone | Medication reminder/adherence/encouragement/recording device | NR | NR | Education and call from nurse within 2 days of antidepressant prescribed | NR | NR | NR | NR | NR | NR | NR | NR | NR | No significant differences in patient compliance with their antidepressant medication among the 3 treatment groups | NR | NR | NR | NR | NR
Taylor | 2006 | Walter Reed Army Medical Center | Sleep disorders center | Homes | RCT | N = 114 CG: 58 Telecare: 56 | October 2002 – March 2003 | 1 month | *Diagnosed with obstructive sleep apnea syndrome (OSAS) *Prescribed CPAP (continuous positive airway pressure) | Current or previous treatment with CPAP or other therapies such as oral appliance or surgery for OSAS. | NR | NR | OSA | NR | UC: 71% Exp Grp: 66% | Mean CG: 44.6 Exp Grp: 45.8 | Caucasian UC: 60% Exp Grp: 49%; African-American UC: 40% Exp Grp: 42%; Hispanic UC: 0% Exp Grp: 5%; Asian UC: 0% Exp Grp: 5% | 0–24999 CG: 20% Exp Grp: 11%; 25000–49000 CG: 21% Exp Grp: 19%; 50000–74999 CG: 25% Exp Grp: 30%; 75000–99999 CG: 20% Exp Grp: 27%; 100000+ CG: 14% Exp Grp: 13% | High school CG: 19% Exp Grp: 20% 2–3 yrs of College CG: 25% Exp Grp: 21%; Technical/Associate Degree CG: 6% Exp Grp 7% Bachelors CG: 25% Exp Grp: 11% Masters Degree CG: 25% Exp Grp: 37% Doctorate+ CG: 0% Exp Grp: 4% | NR | OSAS Severity: Mild CG: 25% UC Exp Grp: 31% Moderate CG: 27% Exp Grp: 35% Severe CG: 48% Exp Grp: 34% | NR (all military-connected) | NR | NR | NR | The Health Buddy | OSAS library with customized information; Daily questions on sleep and CPAP use, responses monitored and categorized into low/medium/high risk, sleep specialist call patient after 3 days of high-risk responses. High≤4 h CPAP use; Medium= 4+ CPAP use but poor sleep; Low=4+ CPAP use and good sleep. | Experimental group: daily patient-entered data on CPAP use, monitoring by sleep specialist. Usual care: clinic visit 1 month after CPAP started, routine access to clinic specialist as needed. | NR | Computerized questions, condition-specific library | NR | NR | Usual care from clinic | NR | NR | NR | NR | NR | Exp group Found HealthBuddy very easy to use: 83% 2 out of 3 reported it a positive experience Had no difficulty using it: 83% Were likely or very likely to continue using it: 75% | Experimental group Satisfied with Health Buddy: 69% Satisfied with communication with clinicians: 71% | NR | NR | Mean hours of CPAP use (hrs): CG: 4.22 Exp Grp: 4.29, p=0.87; CPAP mean proportion (hrs): CG: 50.1% Exp Grp: 46.9%, p=0.61; | Functional status, measured by Modified Functional Outcomes of Sleep Questionnaire (MFOSQ, 8 items, ranges from 0 to 32). UC: 2.27 Exp group: 2.03, p=0.76 | NR | Usual care: 8 subjects did not complete assessments; 1 subject was withdrawn b/c CPAP use was less than 20 days; Exp. Arm: 7 were withdrawn for not activating HealthBuddy, 1 withdrawn for not using it for 30 day observation period, 1 withdrew b/c of choosing an alternative therapy. | NR | NR
Tsang | 2001 | Outpatient clinic | Diabetes hospital clinic | Homes | Randomized cross-over study | N = 19 DMS to Control: 10 Control to DMS: 9 | NR | 6 mos | NR “selected 20 patients from diabetes clinic” | NR | NR | NR | DIABETES | NR | DMS to Control: 50% Control to DMS: 78% | Mean DMS to Control: 30 Control to DMS: 35 | NR | NR | NR | NR | DMS-Control vs. Control-DMS: Duration of illness: 5.3 vs. 11.8 yrs (p=.016); Mean BMI: 22.2 vs. 26 HgA1c: 8.56 vs. 8.81 | NR | NR | NR | NR | “Diabetes Monitoring System” DMS | DMS: Electronic food diary, blood glucose monitoring, email from and to health professionals; Control: usual communication with diabetes clinic | Group 1: used DMS for 12 weeks, then control for 12 wks; Group 2: had control period for 12 weeks, then DMS for 12 wks | Hand-held electronic diary with touch screen | Food and glucose monitoring with feedback | Instruction with 2-week trial period | NR | NR | Mean difference in HgA1c from treatment to control: 0.825% (CI 0.155–1.5) DMS-Control group HgA1c changed from 8.56% to 7.55% (p<0.05) Control-DMS group HgA1c changed from 8.81% to 8.76 to 8.4 (p=.04); | NR | NR | NR | For all 19 subjects: Frequency of use (transmission/week): <1: 3 1–2: 7 3–4: 4 5–6: 2 ≥7: 3 | For all 19 subjects DMS is easy to use: 18 Useful to assess eating: 12 Would recommend: 11 Would use again: 12 | NR | NR | NR | NR | NR | NR | N = 1 | NR | NR
Turnin | 1992 | 150 Km radius of Toulouse, France. (no other details about setting given) | NR | Homes | RCT | N= 105 Group A: 54 pts Group B: 51 pts | NR | 1 yr | *Good command of French, spoken as well as written *Age ≥18 yrs of age. | NR | NR | NR | IDDM and NIDDM | NR | NR | Grp A: 44.8 (±2.0) Grp B: 45.2 (±2.0) | NR | NR | NR | NR | Diabetes (%); Grp A vs. Grp B Insulin dependent: 69 vs. 76 Non insulin dependent: 20 vs. 10 Not insulin dependent insulinated: 11 vs. 14 Occupation (%) Grp A vs. Grp B Working: 74 vs. 75 Unemployed: 26 vs. 25 | NR | NR | NR | NR | Diabeto | A computer assisted diet education system with energy requirement calculation, individualized meal analysis, specially adapted menus and recipes, consultation of the monitoring cardiovascular disease (MONICA) general dietary information, and electronic mail | For the first 6 months, Grp A used diabeto and Grp B were control subjects For the next 6 months, Group B used diabeto and this Grp was followed before and after use of diabeto | Computer | Energy requirement calculation, individualized meal analysis, specially adapted menus and recipes, consultation of the monitoring cardiovascular disease (MONICA) general dietary information, and electronic mail | NR | 1 hr demonstration of the operation of the system and then an individualized demonstration of the operation of minitel when creating its dossier. A book of use is also given to the patient. | NR | Body weight Change Study 1: NS Grp A: 64.7 (±2.0) to 64.6 (±1.9) Grp B: 67.5 (±1.6) to 67.4 (±1.6) For overweight pts, no significant change in body weight between the two phases of the study Grp A: 75.8 (±3.2) and 75.3 (±3.1) Grp B: 75.4 (±3.3) and 74.7 (±3.4) Study 2; NS change Change: 68.5 (±1.7) to 67.0 (±2.3) For overweight pts, significant weight improvement Change: 75.4 (±3.5) to 74.1 (±3.6), p<0.01 Biological variations Study 1: Total HbA1 Change Grp A: 10.7 (±0.4) to 10.1 (±0.4) Grp B: 10.8 (±0.4) to 11.0 (±0.2) Fructosamine Grp A: 4.71 (±0.16) to 4.41 (±0.17) Grp B: 4.82 (±0.13) to 4.78 (±0.13) Study 2: Total HbA1: 11.0 (±0.4) to 9.9 (±0.4), p<0.005 Fructosamine: 5.00 (±0.17) to 4.57 (±0.17), p<0.001 | NR | NR | Study 1: Avg test grades significantly improved for Grp A compared with Grp B The average increased from 56 (±1) to 64 (±2) for Grp A, p< 0.0001 The average decreased from 56 (±2) to 54 (±2) for Grp B Details grades of test 1,2, 3 and 4 given, not listed here. A figure showing that patients knowledge increased with the time that they spent with the system Study 2: Avg grades obtained improved significantly from 56 (±1.5) to 62 (±2.5) p<0.0001 Detailed grades of test 1,2, 3 and 4 before and after use given, not listed here. | Each pt used the system 6 times/month for an avg duration of 15 min/session for a total of 90 min/month 9 pts never used the system 4 pts used it more than 3 hrs/month | NR | Interest in dietetics before use (%) Very low: 2.5 Low: 9.2 Medium: 51.2 High: 26.8 Very high: 4.9 Interest in advantages of diabeto Home access 24 hrs Very low: 0 Low: 2.4 Medium: 4.9 High: 46.3 Very high: 39 Free of charge Very low: 0 Low: 0 Medium: 9.8 High: 22 Very high: 61 Individualized Very low: 0 Low: 0 Medium: 34.7 High: 29.3 Very high: 26.8 Two way dialogue Very low: 4.9 Low: 19.5 Medium: 34.1 High: 19.5 Very high: 14.6 Interest for diabeto options Meal analysis Very low: 0 Low: 2.4 Medium: 4.9 High: 43.9 Very high: 39 Alimentary table Very low: 2.4 Low: 0 Medium: 17.1 High: 36.6 Very high: 34.1 Daily assessment Very low: 0 Low: 7.3 Medium: 9.8 High: 41.5 Very high: 29.3 Energy requirement Very low: 0 Low: 7.3 Medium: 22 High: 39 Very high: 19.5 Dietetic informatics Very low: 0 Low: 7.3 Medium: 19.5 High: 48.8 Very high:14.6 Menus Very low: 4.9 Low: 24.4 Medium: 31.7 High: 22 Very high:- 7.3 Recipes Very low: 4.9 Low: 14.6 Medium: 36.6 High: 22 Very high: 9.8 E mail Very low: 12.2 Low: 24.4 Medium- 22 High: 22 Very high: 4.9 | NR | NR | Study 1; Grp A vs. Grp B Caloric excess Beginning of study, To: 365 (±75) vs. 209 (±37) 6 months, T6: 132 (±81) vs. 238 (±99) Carbohydrate (%) To: 42.2 (±0.8) vs. 40.7 (±0.8) T6: 44.0 (±0.9) vs. 40.7 (+0.7) Carbohydrate deficit(%) To: 39.7 (±0.7) vs. 39.1 (+0.7) T6: 42.9 (±0.9) vs. 40.3 (±0.7) Fat (%) To: 38.3 (±1.0) vs. 38.8 (±0.8) T6: 36.0 (±0.9) vs. 38.5 (±0.8) Fat excess (%) 41.9 (±0.9) vs. 41.4(±0.6) 37.4 (±1.1) vs. 40.0 (±0.7) Study 2; Grp B (beginning vs. 12 months) Caloric excess: 193 (±37) vs. 98 (±49), p<0.05 Carbohydrate (%): 40.3 (±0.9) vs. 42.0 (±1.0), NS Carbohydrate deficit, (%), 38.9 (±0.8) vs. 41.9 (±1.1), p<0.05 Fat (%); 39.5 (±0.8) vs. 38.2 (±1.1), NS Fat excess, 41.2 (±0.6) vs. 39.4 (±1.2), NS | NR | NR | First study 9 pts lost to study in minitel grp (never used the system, 2 for personal reasons, 2 for lack of time, 1 moved and 4 could not be accounted for), In the control grp 1 pt moved and was lost to the study Second study 6 pts dropped out, (5 between 6th and the 12th month) | NR | The author says that factors favorably influencing the amount of use of the system were the patients interest in dietetics and their amount of free time. Retired people and those not employed made the most use of the system The author also says that the possibility of unlimited use with free access 24 h/day in their own homes was an important factor in motivating the pts to monitor their diet
van den Berg | 2007 | Rheumatology outpatient clinics | 3 Teaching hospitals | Homes | RCT | N = 160 Grp 1: 82 Grp 2: 78 | March 2003–August 2004 | 12 mos | *Dx of RA *Physical activity of at least 30 mins a day at least 5 days/week *Access to a computer with internet capabilities *Able to cycle on a bicycle ergometer *No cardiopulmonary conditions which would not allow moderately intensive physical activity | NR | NR | NR | RHEUMATOID ARTHRITIS | NR | Grp 1: 24% | Median at Baseline Grp 1: 49.5 | NR | NR | Grp 1: Low education level: 18% Medium education level: 61% High education level: 21% | NR | NR | NR | NR | NR | NR | NR | Web-based system for reporting physical activity and receiving personalized exercise schedules | Group 1: Intervention group (only one mentioned in this paper) Group 2: General training group (data reported elsewhere) | Web-based intervention | Education, personalized exercise schedule, data input and sending | Some Homes visits were offered to assist subjects | NR | NR | NR | NR | NR | NR | Over the follow-up period, 70% of Grp 1 logged into the system at least once a week | NR | The majority of individuals were satisfied or very satisfied with the system variation and clarity (87% and 94%, respectively). The majority of individuals were satisfied with the frequency of contact with their PT. 55/62 (89%) reported they did not experience any miscommunications between themselves and their PT due to the use of email. | NR | NR | Individuals who logged in more frequently participated in more moderate intensity and vigorous intensity physical activity than those who logged in less frequently, at 12 month follow-up (P=0.036 and P=0.001, respectively) | RAQoL: Those that reported more often on their physical activity schedules reported significantly greater improvements than those that reported less often (P=0.01) | NR | 5 from Grp 1 lost to follow-up | NR | NR
Van den Brink | 2005 | NR | Tertiary health care center | Homes | Cohort | N= 36 | September 2000–January 2002 | 6 weeks | *Pts were eligible if they had undergone a laryngectomy, a commando procedure (removal of a tumor in the mouth or throat by splitting the lower jaw) or a neck dissection (removal of the lymph nodes in the neck) *Pts also needed to be able to read and write Dutch *Have a phone at home. | NR | NR | NR | HEAD AND NECK CANCER | NR | N = 26 pts (72.2%) | Mean (Range): 59 (38–78) | NR | NR | No education: 0 pts Elementary school: 6 pts Lower technical school: 14 pts Secondary education: 6 pts Middle technical training: 2 pts High school/College: 3 pts Higher education: 3 pts University level: 2 pts Information about marital status given, not listed here | NR | 20 pts (56%) had no experience with computers before participation | NR | NR | NR | NR | Electronic health information support system | Electronic health information system with four different functions, namely, communication, information, contact with fellow sufferers and monitoring of discharged patients in head and neck cancer care. | The electronic support system consisted of the following features Communication: Pts as well as health care providers able to create messages with the subject and type of message, stored centrally. Each pt had own PO box. Information: specially developed website containing general information on cancer treatment of H and N cancer, rehabilitation after treatment, and links to other relevant websites Contact with fellow sufferers: forum where pts could discuss any subject, either anonymously or with their own name. Monitoring: Pts completed electronic monitoring questionnaires on a regular basis after discharge. E-mail alerts: when an abnormal answer appeared in the questionnaire or pt classifies response as question, an email alert generated and sent to the support team in the hospital. | Computer | Email alerts, electronic monitoring questionnaires, forum, information | Involved health care providers received information on how to use the system and were provided with access passwords | Medical student trained and supervised pts while the patient practice use of the system in the hospital | NR | NR | NR | NR | NR | Total number of patient sessions: 982 Average: 27.3 (±18.4), Range: 4–69 On average, a pt session lasted 12 mins. 16% took place after office hours Details about usage by health care provider also given, not listed here | Encountered difficulty (technical problems) while using the system: 9 pts (25%) Reasons given: system did not work anymore (3 times), too slow (3 times), password forgotten (once), handling the mouse was difficult (once), computer refused to switch off (once) Additional remarks made by pt quoted- not listed here Felt that being able to contact care providers by means of the system provided a feeling of security: 83% Found that learning how to use the system was not difficult at all: 61% | Use and appreciation of the electronic health information system Monitoring Pts using this functionality: 36 (100%) % of satisfied patient users: 94% (31/33) Mean score (Range): 8.0 (2–10) Ask questions Pts using this functionality: 23 (64%) % of satisfied patient users: 91 (21/23) mean score (Range): 7.8 (1–10) Read messages Pts using this functionality: 27 (75%) % of satisfied patient users: 89 (24/27) Mean score (Range): 7.7 (4–10) Contact with fellow sufferers Pts using this functionality: 3 (8%) % of satisfied patient users: 67 (2/3) Mean score (Range): 6.7 (6–8) Information Pts using this functionality: 22 (61%) % of satisfied patient users: 91 (20/22) Mean score (Range): 7.8 (1–10) Overall score for the system as a whole Mean score (Range): 8.0 (4–10) | NR | NR | NR | NR | NR | During the inclusion period, 59 met the criteria for inclusion 20 refused to participate (inclusion of 66%) Computer phobia: 9 times Tiredness/need rest: 4 times Does not like idea of filling paper questionnaires- 2 times Looks after demented parent-1 Moving house- 1 Partner does not allow pt to have access to computer- 1 No time- (company ownership)- 1 Afraid of theft of laptop computers- 1 Moreover; 3 stopped shortly after inclusion 2 were too tired to participate 1 died | NR | A table detailing information about - subjects of questions generating email alerts given, not listed here. Additional remarks made by pts about the system quoted, not listed here List of questions asked in the patient's questionnaire with patient answers given, results from the GP's questionnaire also given
Van der Meer | 2007 | NR | 19 general practices, (44 GP's) Out patient clinic of department of pediatrics of Leiden University Medical Center, Netherlands | Homes | Cohort | N= 97 | NR | 1 month follow up (monitoring) after which subjects invited to participate in focus groups | *Physician diagnosed asthma *Age 12–17 yrs *Use of inhaled corticosteroids for at least 3 months in the previous year *No serious co morbid conditions that interfered with asthma treatment *Access to internet at home *Ability to understand Dutch | NR | NR | NR | ASTHMA | NR | Pts with well controlled asthma: 55.5% Pts with poorly controlled asthma: 41% p=0.51 | Pts with well controlled asthma (well): 14.2 (±1.7) Pts with poorly controlled asthma (poor): 14.7 (±1.5) p= 0.36 | NR | NR | NR | NR | Duration of asthma, Mean years, (%) Well: 7.4 (4.9); Poor: 8.8 (5.1) Current prescription inhaled corticosteroids, n Well: 17; Poor: 17 Details of care provider also given | NR | NR | NR | NR | Internet based self management for better asthma control | Adolescents with mild to moderate persistent asthma monitored their asthma control on a website with return message containing their FEV1 and peak expiratory flow values expressed as percentages. After 4 weeks of monitoring, pts invited to take part in eight focus groups.(more on Van der Meer et al 2006) | All pts received a hand held electronic spirometer and were trained to perform three maneuvers every morning before receiving medication, and to report FEV1 and peak expiratory flow values by entering them daily into a designated web application or via SMS during a 1 month period. Pts received return message with FEV1 and peak expiratory flow values expressed as a percentage of expected or best value. (Methods described in detail in Van der meer et al, 2006. Following the electronic monitoring study, eight focus group sessions lasting 1– 1.5 hrs were conducted where pts were stratified according to asthma control, gender and age. | Computer, cell phone | Data log in, return messages. | NR | Trained to perform spirometry three times before medication | NR | Well vs. Poor ACQ score 0.6 (±0.3) vs. 1.9 (±0.5), p<0.01 ATAQ control score 0 (±0) vs. 2 (±1.8), p<0.01 Prebronchodilator FEV1, % Predicted, Mean (SD) 100.7 (±20.9) vs. 90.7 (±17.7), p=0.14 | NR | NR | NR | NR | Majority of the participants felt that sending lung function values and symptom scores via the internet or SMS was easy and fast. | Barriers and benefits of internet based self management: Well vs. Poor, n (%) Internet based monitoring: electronic monitoring is feasible: 15 (83) vs. 15 (88), p=1.00 Recognize benefits of internet based monitoring: 1 (6) vs. 4 (24), p=0.18 Internet information: need for comprehensive information: 3 (17) vs. 5 (29), p= 0.44 Positive features of internet information: 11 (61) vs. 12 (71), p=0.73 Internet based action plan: able and ready to use internet based action plan: 2(11) vs. 11 (65), p<0.01 No need to use action plan at all: 14 (78) vs. 3 (18), p<0.01 | NR | Well v. Poor KASE-AQ Attitude: 3.7 vs. 3.8, p=0.55 Self-efficacy: 4.0 vs. 3.6,p=0.046 Intrinsic barriers to current asthma management Negative attitude towards asthma management Well vs. Poor 2 (11) vs. 3 (18), p=0.66 Limited perceived ability to manage asthma Well vs. Poor 3 (17) vs. 11 (65),p<0.01 Barriers and benefits of internet based self management: Internet based medical review Positive attitude towards electronic consultation: 8 (44) vs. 10 (59), p=0.51 Negative attitude toward electronic consultation: 2 (11) vs. 2 (12), p=1.00 | NR | NR | Intrinsic barriers to current asthma management Negative social influences Well vs. Poor; 0 (0) vs. 3 (18), p=0.11 | Invited to participate in one month internet based monitoring study, n=180 No informed consent= 79 Withdrawal from monitoring study= 4 Complete internet based monitoring study=97 Contradictory scores on ACQ and ATAQ control domain= 17 Eligible for focus group discussion= 80 | Expressions of acceptance of asthma symptoms given, not listed here | Barriers and drivers for HIT use Attitude towards asthma management: 3 pts with poorly controlled asthma were bothered by face to face medical reviews, since they learned to live with their symptoms and saw no need for regular consultations (driver for HIT use) Views on barriers and benefits of internet based asthma self management: Pts thought that internet based monitoring and reporting was feasible, not time consuming and did not interfere with their daily activities. Also sending lung function values and symptom scores was easy and fast. Pts in the well controlled group had fun doing the measurements but did not think that it is useful and did not observe any benefits from daily electronic monitoring and feedback as they did not have any symptoms at the time. Pts with poorly controlled asthma reported the usefulness of daily monitoring stating that being able to react to changes in asthma were personal benefits of the system. All pts said that the internet is easy to use and accessible and is not boring as there are opportunities to show graphics and short films, and if information is offered, it should be offered through the internet. Three patients mentioned that doctor visits were annoying and pts preferred to visit their doctor only when symptoms get worse.(driver for use) All pts mentioned that email communication and electronic communication were very useful (driver)
Weinert | 2005 | Clinics where patients with CI visited | Montana, Idaho, North Dakota, South Dakota, Wyoming | Unclear | Three group | N=63 | 2 years | NR | *Live at least 25 miles outside of an urbanized area (city of ≥12,500) *Live with a CI | *Live within 25 miles of urbanized area *No CI | Mean age = 54.1 | YES | Diabetes, Rheumatoid condition, Heart disease, Cancer, MS | NR | 0 | Mean (Range) 54.1 (38–66) | White: 96.8% Hispanic: 1.6% Native American: 1.6% | 0–15,000: 20.6% 15,000–24,999: 12.7% 25,000–34,999: 11.1% 35,000–44,999: 15.9% 45,000–54,999: 19.0% ≥55,000: 18.9% | Mean (SD) 14.5 (±1.95) | YES: lived at least 25 miles outside of urbanized area Number of miles to routine health care: 60.7 (±82.36) | None | NR | NR | NR | NR | NR | Online health teaching units with expert facilitated discussions, internet access, and a self-help social support group | Grp 1: online teaching units + expert facilitated discussion + self-help social support group Grp 2: online teaching units Grp 3: CG | Computer/internet | lessening depression and isolation and bolstering social support, develop computer skills, acquire internet skills | NR | NR | NR | NR | NR | NR | Self-rated computer skills at baseline: IVR: 4.66 (±1.75) CG: 5.32 (±2.07) Self-rated computer skills at 18mos: IVR: 5.93 (±1.51) CG: 5.26 (±1.94) | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Wilkie | 2001 | Radiation and medical oncology outpatient clinics. | Large medical center | In clinical exams rooms at radiation and medical oncology outpatient clinics. | Cohort | N = 41 *All completed SymptomReport CG: 19 IVR: 22 | NR | 5 weeks | *Cancer diagnosis Have pain, fatigue, or both *English literate *Ages ≥ 18 yrs *Physically and cognitively able to complete the study | Blind patients and non-English speaking patients were excluded from the study. | NR | NR | CANCER DIAGNOSIS AND CHRONIC PAIN | NR | N = 10 (24%) | Mean (SD): 52 (± 12.4) Range: 28–78 | Caucasian: 40 pts Asian: 1 pt | NR | HS: 23% Vocational School: 8% Associate Degree: 25% Bachelor's Degree: 25% Master's Degree: 10% Doctoral Degree: 3% Other: 8% | NR | Married: 69% Single: 28% Widowed: 3% | NR | NR | NR | NR | SymptomConsult | NR | All (41) completed SymptomReport. They then completed the SymptomConsult program. 19 were randomized to choose 1 of 3 computer games. 22 were randomized to view tailored educational materials; reporting pain, safe use of pain medicines, and managing fatigue. | Fujitsu 1600 pentab computer with Windows 98-based SymptomReport program. (touch screen computer) | The SymptomReport program was designed as an interactive, touch-screen method for assessment of pain and fatigue. This is an electronic version of the 1970 edition of the McGill pain questionnaire (MPQ), the pain barriers questionnaire (BQ), and the Schwartz cancer fatigue scale (SCFS-6). | The researcher instructed the patient to read and touch the computer screen to start. The researcher provided assistance in completing the computerized SymptomReport if asked by the patient and then documented the assistance provided. | The researcher instructed the patient to read and touch the computer screen to start. The researcher provided assistance in completing the computerized SymptomReport if asked by the patient and then documented the assistance provided. | NR | NR | NR | NR | The Symptom Consult program seemed to increase patients' understanding of the symptoms, raise their awareness of pain and fatigue, and enhance compliance with symptom management. | Fewer patients completed the computer items the second time, usually because of time constraints or a desire to skip questions not relevant to their clinical situation. | Average time spent viewing SymptomConsult: 20 minutes. Fatigue intervention: 7 minutes. Each pain intervention component: 1–16 minutes. | The majority of participants (71%) indicated that the computer program was easy, enjoyable, informative, and a good tool. | NR | NR | Intervention provided a chance to think more and helped enrich communication with doctors. | NR | NR | NR | Patients complained of repetitive questions, especially if the pain questions didn't personally apply. | NR
Williamson | 2006 | NR | NR | Homes | RCT | N = 57 | NR | 2 years | *African American girls between 11–15 yrs *BMI above 85th percentile for age and gender *At least one obese biological parent as defined by BMI>30 *One designated parent who was overweight BMI>27 and was willing to participate in the study *Adolescent's family was willing to pay $300 out of pocket expenses toward the purchase of a computer worth $1000 *Family home had electricity and at least one functional telephone line | NR | No | All African Americans | Obesity | NR | 0 | Adolescents: 13.2 (±1.4) Parents: 43.2 (±6.2) | African Americans | NR | NR | NR | Height (cm) Adolescents: 160 (±8.1) Parents: 162.3 (±6.9) Weight (kg) Adolescents: 93.3 (±22.5) Parents: 101.2 (±18.4) BMI Adolescents: 36.4 (±7.9) Parents: 38.4 (±7.2) Body fat DXA (%) Adolescents: 45.9 (±7.5) Parents: 48.4 (±6.3) BMI Percentile Adolescents: 98.3 (±2.5) | NR | NR | NR | NR | HipTeens | Interactive Internet based lifestyle behavior modification program for African American girls over 2 year period. Web based program providing nutrition education and behavior modification by asynchronous email communication and links to culturally competent websites and interactive components such as weight and activity graphs, food intake monitoring with counselors providing feedback on the same. | Grp 1: Control Grp 2: Behavioral Both the groups had the following: 4 face to face counseling session during the first 4 weeks, Weight graph, email to study staff, links to African American health websites, links to women's health website. In the lessons to be read by adolescents and parents, the control grp had lessons for healthy lifestyle whereas the behavioral grp had lessons promoting dietary and behavioral exercise change. Apart from the above, the behavioral grp had physical activity graph, food monitoring with feedback using traffic light diet, rate your plate exercise for healthy eating habits, behavioral contracting with parent, adolescent, counselor; problem solving to overcome obstacles, goal setting for change, TV self monitoring to reduce sedentary behavior, quizzes that tested knowledge related to weekly lessons. | Computer | E mail, links to website, activity graphs, monitoring of daily food intake and physical activity | The counselors were educated on culturally relevant dietary and physical activity issues, and they incorporated this information into face to face and internet counseling sessions. | Adolescents and parents were trained to set up their new computers at home, access and use the website, and use email to communicate with their counselor by the internet. | NR | Grp 1 vs. Grp 2 – 24 months Weight (kg) Adolescents: 6.3 (±1.6) vs. 4.4 (±1.7) Parents: -0.60 (±0.89) vs. - 1.1 (±0.91) BMI Adolescents: 1.2 (±0.65) vs. 0.73 (±0.66) Parents: 0.04 (±0.34) vs. -0.55 (±0.34) Body fat DXA (%) Adolescents: 0.84 (±0.72) vs. -0.08 (±0.71) Parents: 0.51 (±0.46) vs. 0.36 (±0.46) BMI Percentile Adolescents: -0.001 (±0.003) vs. -0.004 (±0.003) Body weight at baseline significant co variate for body weight changes of parents F (1, 54)= 27.2, p < 0.0001 Baseline BMI percentile significant co variate for changes in BMI percentile, F (1, 54) = 10.89, p< 0.001 significant overall effect of treatment for parental changes in BMI F (1, 54)= 4.78, p< 0.04 Significant changes over time for adolescent changes in body weight, F (3,54)= 6.55, p< 0.001 BMI percentile changes, F (3,54)= 4.14, p<0.02 BMI, F (3,54)= 3.13, p<0.04 | NR | NR | NR | Figure showing mean website hits, activity graph and weight graph hits given, difficult to get the exact numbers Significant differences in website use between the 2 grps for both adolescents and parents in the first year Adolescents: F (1,55)= 4.95, p< 0.05 Parents: F (1, 55)= 4.15, p<0.05 Second year- difference diminish; almost equal in both grps (very reduced web usage) | NR | NR | NR | NR | Dieting and weight concerns of adolescents, Time* treatment approached significance- F (3, 48)= 2.44, p< 0.08 Adolescents (Control grp) decreased dieting and weight concerns during first 6 months, bt scores returned to baseline levels during the next 18 months Adolescents in both grps reported improvements in exercise and over eating as compared to baseline.(p<0.05) Adol in behavioral grp reported eating less fattening foods as compared to control F (1, 48)= 2.08, p< 0.05 Parents in behavioral grp reported more exercise than the control F (1, 49)= 4.10, p< 0.05 Parents in behavioral grp reported greater reductions in over eating Parents in both grps reported improvements in avoidance of eating fattening foods during 24 month trial in comparison with baseline. | NR | NR | Seven families dropped out of control (24%) and 10 dropped out of treatment (36%) Difference NS | NR | Baseline characteristics of the sample including height, weight, BMI, Body fat DXA, BMI percentile given, not listed here. Figure showing mean website hits, weight graph hits and activity graph hits given, not listed here Figure showing changes in weight loss behaviors from baseline for both parents and adolescents given, not listed here NS results showing parents in behavioral grp reporting more comfort and interest with computers at baseline showed trends for more website hits and email use during 2nd yr of study Behavioral correlates of changes in adiposity given, not listed here
Winzelberg | 2003 | Public service announcements on local radio, in newspapers and flyers in oncology offices in SFBay and LA | NR | Homes | Randomized clinical trial | N = 72 Grp 1: 36 Grp 2: 36 | NR | 3 mos | *Female *Receiving a primary breast carcinoma diagnosis within 32 mos *Not suicidal *Living in CA *Communicate in written English | NR | YES | NR | BREAST CANCER | NR | N = 0% | Mean (SD): 49.5 (±6.2) Range: 30–69 | Caucasian: 80% African-American: 4% Asian: 4% Hispanic/Latina: 6% Other: 6% | NR | Some graduate school: 36% Bachelor's Degree: 28% Some college: 28% Trade School: 1% <HS: 7% | NR | Married: 68% Single: 15% Divorced: 11% Widowed: 4% Separated 1% 34% were in a breast cancer support group or individual counseling at baseline | NR | NR | English | NR | Bosom Buddies | 12 week, structured, web based support group moderated by a mental health professional | Group 1: Intervention Group 2: Wait-list control | Website | Support group, online diary, read survivors stories, | NR | Those who were given computers to use for the study were “instructed” on their use | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | Group experience evaluation (% reporting a lot or a great deal) Getting support and encouragement: 65 Helping others: 56 Learning that problems are not unique: 56 Develop new friendships: 63 Get advice: 55 Express true feelings: 65 Model self after group participants: 30 Confront difficult probs. and fears: 44 Discuss sexual concerns: 44 | NR | NR | Psychological: CES-D: F=6.00 (p<0.01) PCL-C: F=8.36 (p<0.01) PSS: F=3.88 (p<0.05) STAI: F=.78 Cancer Behavior Inventory F scores Seeking support: .59 Seeking understanding: 0.03 Coping: 0.19 Affect Regulation: 0.07 Positive Attitude: 0.40 Activity/Independence: 0.00 MiniMac Helpless/hopeless: 0.21 Anxious/preoccupation: 0.90 Fighting spirit: 0.95 Cognitive avoidance: 1.02 Fatalism: 0.45
Woodruff | 2001 | Rural alternative schools | NA | School computer | Pre-post cohort study | N = 26 | NR | 3 months | *Age 13 to 18 *Obtain parental consent *Smoked 1 cigarette in past month | NR | NR | NR | SMOKING | NR | N = 66% | Mean: 15 | Caucasian: 55% Hispanic: 28% Other: 17% | NR | Alternative school | Rural | NR | NR | NR | NR | NR | Breathing Room | Counselor-facilitated chat room All users logged onto weekly, 1-hour sessions for 7 weeks | NR | Website | Chatroom, facilitated by tobacco counselor, using Active World (avatars) | NR | NR | NR | NA | NA | NA | NR | NR | NR | NR | NR | NR | 38.9% self-reported not smoking | NR | NR | NR | NR | NR
Yon | 2007 | NR | NR | Homes | Cohort with historical control | N= 176 PDA Grp: 61 CG: 115 | NR | 24 months | *Age ≥ 18 yrs *BMI > 25 and ≤ 39 kg/m^2^ *Regular access to a computer (not less than 3 yrs old with CD Rom drive, internet connection, at least 64 megabytes of RAM, 350 MHz processor speed and windows 98 or higher as a computer operating system) | Pts ineligible if they planned a pregnancy or to move from the area within the next 12 months, had a history of major medical or psychiatric problems, took medications that had implications for weight loss, were unable to participate in a mild to moderate exercise program, or unable to regularly attend weekly meetings. | NR | NR | OBESITY | NR | Grp 1: 8 (5%) Grp 2: 16 (19%) | Mean age (SD) Grp 1: 48.2 (±8.7) Grp 2: 46.1 (±9.2) | NR | NR | High school/Vocational school Grp 1: 10% Grp 2: 7% Some college Grp 1: 11% Grp 2: 30% College degree Grp 1: 18% Grp 2: 34% Graduate/Professional degree Grp 1: 22% Grp 2: 44% | NR | Marital status (%), p< 0.001 Grp 1 vs. Grp 2 Married/civil union: 43 vs. 86 Separated/divorced/widowed: 13 vs. 29 Never married: 5 vs. 0 Computer ability (%) Grp 1 vs. Grp 2 Novice/basic software: 10 vs. 8 Software + internet: 41 vs. 77 Hobbyist: 5 vs. 25 Professional: 5 vs. 5 | NR | NR | NR | NR | Calorie King's Diet diary | Use of the Calorie king software to self monitor food intake and exercise installed in Palmzire 21 | Pts given printed lessons for review each week, facilitated by a master' s level grad student, pts instructed to reduce energy intake, individual calorie goals determined, graded goals for programmed physical activity was used, pts encouraged to increase lifestyle exercise, Grp 1: PDA grp-instructed to self monitor food and exercise with the software, pts electronically submitted their food and exercise diary weekly at group meeting by using the hot-sync function, positive feedback self-monitoring behavior and support provided via weekly email messages from the group facilitator to each subject. Grp 2: small paper weekly diaries provided and a book with calorie listings of food. The diary was handed to the facilitator at weekly meetings and positive feedback was provided. | PDA | Weight and exercise data | NR | Initial orientation and consent, second orientation session for baseline data collection and technical support and assistance for the PDA and calorie King software provided. | NR | Mean weight loss, kg (SD) Grp 1 vs. Grp 2 6.3 (±6.1) vs. 7.2 (±5.2), F (1, 145)= 0.17, p= 0.68 Mean % weight loss (SD) Grp 1 vs. Grp 2 7 (±6.5) vs. 8.3 (±5.8), F (1, 145) = 0.99, p=0.32 All subjects Mean weight loss, kg (SD) Grp 1 vs. Grp 2 5.8 (±6.1) vs. 5.8 (±5.5), F (1,145) = 0.04, p=0.84 | NR | NR | NR | Most pts reported making entries regularly throughout or at the end of the day (61%) Pts entered most or all of the food they consumed (80%) and most of all of the programmed exercise (71%) | The following aspects were liked by the pts Ability to look up calorie and nutritional information: 65% Portability: 47% Convenience: 34% Ease of entering food and exercise data: 26% Disliked PDA as unable to find commonly eaten food and it was hard to see the screen: 44$ | NR | NR | NR | NR | NR | NR | PDA group: 57 completers (7 % withdrew) Control group: 93 completers (19% withdrew) | NR | Correlation between dietary self monitoring and weight loss (ANCOVA results) relationship between attendance and weight loss, relationship between compliance and calorie goals and weight loss and between exercise goals and weight loss given, not listed here
Zabinski | 2001 | Public West coast university | NA | Homes | Cohort | N= 4 | NR | 10 weeks | *Self reported high body image concerns *Failed to report substantial depressive symptomatology *Did not report thoughts of harming themselves or others | Pts who self reported a past or current eating disorder diagnosis | NR | NR | NR | NR | N = 0% | Mean (Range): 19.4 (18–20) | Caucasians: 2 pts (50%) Asian: 1 pt (25%) Hispanic/Latina: 1 pt (25%) | NR | Freshmen in College: 3 Sophomore in College: 1 | Urban | NR | NR | NR | NR | NR | Internet Relay Chat (IRC) | Chatroom in a public site (yahoo), consisting of electronic newsgroup and a chat room. Forum for pts to discuss reactions to chat, readings and assignments via asynchronous postings moderated by the author | 3 components to the treatment. Weekly readings, chat discussions, and summaries of each chat discussions. At the beginning of each week, pts received single page of reading, logged on to the chat room for an hour, moderator assigned homework, and allowed pts to express their feelings, moderator e mailed one page summary of the chat. | Computer | Interactive chat room, asynchronous postings on the net | NR | Instruction manual and contact number of the research assistant given | NR | Measure - M (SD) Baseline vs. Post Tx vs. 10 week follow up Effect sizes Baseline to Post Tx ; Post Tx to follow up Eating disorder inventory ----bulimia subscale 10.0 (1.4) vs. 10.5 (2.4) vs. 12.0 (7.4) -0.36 ; -0.63 ----Drive for thinness subscale 19.5 (12.5) vs. 20.0 (15.2) vs. 15.8 (6.2) -0.04 ; 0.28 Eating disorders examination questionnaire Global 1.5(1.2) vs. 1.1 (1.0) vs. 0.7 (0.7) 0.33 ; 0.40 Weight 1.8(1.3) vs1.5(1.6) vs. 0.7(0.5) 0.33 ; 0.40 Shape 2.2(1.3) vs. 1.3 (1.3) vs. 0.9 (0.7) 0.69;0.31 Eating 0.7 (1.0) vs. 0.4(0.4) vs. 0.25 (0.4) 0.30;0.25 Restraint 1.3(1.6) vs. 1.4(1.3) vs. 0.9 (1.7) -0.06;0.38 Body shape questionnaire 96.0 (48.3) vs. 82.3(41.7) vs. 66.5 (32.9) 0.28; 0.38 Rosenberg self esteem scale 25.0(3.8) vs. 24.0(2.0) vs. 25.0(2.4) BMI 20.5(2.9) vs. 20.5(2.6)vs. --- | NR | NR | NR | Members participated in 79% of the sessions. Pts who missed a chat session contacted moderator for update (contacts unprompted) | Easier for pts to be honest with the computer- acceptability was high. | Pts rated their satisfaction with the program really high Table 2 lists specific responses from the participants with raw scores-not listed here | Pts reported that the intervention helped prevent negative attitudes about their weight and shape making them feel bad and to recognize the thoughts and situations that trigger negative feelings or behaviors (4 or higher on 7 point scale) 3 pts also reported that the intervention helped them to challenge negative thought patterns (5 or higher on a 7 point scale). Table 3 gives ratings of perceived change with pt responses, not listed here | NR | NR | NR | NR | NR | NR | Qualitative responses of pts given
Zimmerman | 2004 | Large tertiary hospital where pts who were admitted for elective CABG over a 9 month period | NR | Homes | RCT | N=52 | NR | 6 months | *Age ≥ 65 years *1st CABG surgery *Not visually/hearing impaired *English literate *No apparent physical impairments that would limit their physical functioning after surgery | Any criteria against the Inclusion criteria | YES | NR | CABG | NR | 72% | 71.22 (65–79) | 100% Caucasian | NR | NR | NR | NR | NR | English literate | English | NR | Health Buddy | CABG patients access web for daily information on recovery, provider can observe patients' progress at home | IVR: 24 UC: 21 | Website | Data input, receiving information | NR | NR | NR | Frequency of Evaluation of Symptoms by Group at 2, 4, and 6 weeks Fatigue 2 week, 4 week, 6 week UC: 6, 11, 8 IVR: 7, 13, 11 Sleep 2 week, 4 week, 6 week UC: 11, 5, 8 IVR: 12, 9, 7 Swelling 2 week, 4 week, 6 week UC: 7, 3, 3 IVR: 11, 8, 9 Shortness of Breath 2 week, 4 week, 6 week UC: 6, 3, 2 IVR: 7, 8, 5 Incisional Pain 2 week, 4 week, 6 week UC: 6, 3, 2 IVR: 8, 6, 6 Appetite 2 week, 4 week, 6 week UC: 8, 6, 4 IVR: 7, 2, 3 Anxiety 2 week, 4 week, 6 week UC: 1, 4, 3 IVR: 4, 6, 1 Depression 2 week, 4 week, 6 week UC: 1, 3, 2 IVR: 4, 4, 0 Fluttering 2 week, 4 week, 6 week UC: 3, 2, 2 IVR: 4, 3, 3 Angina 2 week, 4 week, 6 week UC: 1, 1, 0 IVR: 1, 0, 1 | NR | NR | NR | NR | NR | NR | NR | NR | Mean Scores of Symptom interference on physical functioning at 2, 4, and 6 weeks Fatigue 2 week, 4 week, 6 week UC: 1, 1.36, 1.12 IVR: 1.6, 1.4, 0.76 Sleep 2 week, 4 week, 6 week UC: 0.84, 0.48, 0.64 IVR: 0.2, 0.6, 0.28 Swelling 2 week, 4 week, 6 week UC: 0.32, 0.12, 0.12 IVR: 0.64, 0.44, 0.36 Shortness of Breath 2 week, 4 week, 6 week UC: 0.52, 0.28, 0.08 IVR: 0.6, 0.76, 0.2 Incisional Pain 2 week, 4 week, 6 week UC: 1.04, 0.76, 0.36 IVR: 0.72, 0.6, 0.56 Appetite 2 week, 4 week, 6 week UC: 0.44, 0.88, 0.84 IVR: 0.28, 0.24, 0.44 Anxiety 2 week, 4 week, 6 week UC: 0.04, 0.48, 0.12 IVR: 0.4, 0.24, 0.04 Depression 2 week, 4 week, 6 week UC: 0.04, 0.12, 0.28 IVR: 0.16, 0.16, 0.08 Fluttering 2 week, 4 week, 6 week UC: 0.12, 0.4, 0.24 IVR: 0.68, 0.24, 0.24 Angina 2 week, 4 week, 6 week UC: 0.12, 0.2, 0 IVR: 0.24, 0, 0.04 | Mean Scores of symptom interference on enjoyment of life at 2, 4, and 6 weeks Fatigue 2 week, 4 week, 6 week UC: 1.12, 1.0, 1.08 IVR: 1.32, 0.88, 0.68 Sleep 2 week, 4 week, 6 week UC: 0.92, 0.68, 0.68 IVR: 0.56, 0.6, 0.44 Swelling 2 week, 4 week, 6 week UC: 0.28, 0.12, 0.12 IVR: 0.52, 0.44, 0.36 Shortness of Breath 2 week, 4 week, 6 week UC: 0.52, 0.12, 0.04 IVR: 0.76, 0.56, 0.2 Incisional Pain 2 week, 4 week, 6 week UC: 1.04, 0.76, 0.36 IVR: 0.4, 0.36, 0.32 Appetite 2 week, 4 week, 6 week UC: 0.24, 0.84, 0.76 IVR: 0.28, 0.2, 0.4 Anxiety 2 week, 4 week, 6 week UC: 0.04, 0.52, 0.12 IVR: 0.04, 0.52, 0.12 Depression 2 week, 4 week, 6 week UC: 0.04, 0.16, 0.28 IVR: 0.36, 0.24, 0.08 Fluttering 2 week, 4 week, 6 week UC: 0.12, 0.48, 0.08 IVR: 0.32, 0.24, 0.32 Angina 2 week, 4 week, 6 week UC: 0.04, 0.2, 0 IVR: 0.04, 0, 0.04 | NR | N=7 3 were readmitted to a healthcare facility and were unable to obtain healthcare data for over a week 1 moved 1 had a rotary telephone 2 did not want to be contacted | NR | NR

## References for Appendix H

Albisser AM, Harris RI, Albisser JB, Sperlich M. The impact of initiatives in education, self-management training, and computer-assisted self-care on outcomes in diabetes disease management. Diabetes Technology & Therapeutics. 2001;3(4):571-579. [pmid: 11911169].
An LC, Perry CL, Lein EB, Klatt C, Farley DM, Bliss RL, et al. Strategies for increasing adherence to an online smoking cessation intervention for college students. Nicotine & Tobacco Research. 2006;8(Suppl 1):S7-12. [pmid: 17491165].
Andersson G, Bergstrom J, Hollandare F, Carlbring P, Kaldo V, Ekselius L. Internet-based self-help for depression: randomised controlled trial. British Journal of Psychiatry. 2005;187:456-461. [pmid: 16260822].
Andersson G, Carlbring P, Holmstrom A, Sparthan E, Furmark T, Nilsson-Ihrfelt E, et al. Internet-based self-help with therapist feedback and in vivo group exposure for social phobia: a randomized controlled trial. Journal of consulting and clinical psychology. 2006;74(4):677-686. [pmid: 16881775].
Andersson G, Lundstrom P, Strom L. Internet-based treatment of headache: does telephone contact add anything?. Headache. 2003;43(4):353-361. [pmid: 12656706].
Andrade ASA, McGruder HF, Wu AW, Celano SA, Skolasky RL Jr, Selnes OA, et al. A programmable prompting device improves adherence to highly active antiretroviral therapy in HIV-infected subjects with memory impairment. Clinical Infectious Diseases. 2005;41(6):875-882. [pmid: 16107989].
Andrewes DG, O'Connor P, Mulder C, McLennan J, Derham H, Weigall S, et al. Computerised psychoeducation for patients with eating disorders. Australian & New Zealand Journal of Psychiatry. 1996;30(4):492-497. [pmid: 8887699].
Anhoj J, Nielsen L. Quantitative and qualitative usage data of an Internet-based asthma monitoring tool. Journal of Medical Internet Research. 2004;6(3):e23. [pmid: 15471749].
Araki I, Hashimoto H, Kono K, Matsuki H, Yano E. Controlled trial of worksite health education through face-to-face counseling vs. e-mail on drinking behavior modification. Journal of Occupational Health. 2006;48(4):239-245. [pmid: 16902267].
Armstrong K, Weber B, Ubel PA, Peters N, Holmes J, Schwartz JS. Individualized survival curves improve satisfaction with cancer risk management decisions in women with BRCA1/2 mutations. Journal of Clinical Oncology. 2005;23(36):9319-9328. [pmid: 16361631].
Artinian NT, Harden JK, Kronenberg MW, Vander Wal JS, Daher E, Stephens Q, et al. Pilot study of a Web-based compliance monitoring device for patients with congestive heart failure. Heart & Lung. 2003;32(4):226-233. [pmid: 12891162].
Bachofen M, Nakagawa A, Marks IM, Park JM, Greist JH, Baer L, et al. Home self-assessment and self-treatment of obsessive-compulsive disorder using a manual and a computer-conducted telephone interview: replication of a UK-US study. Journal of Clinical Psychiatry. 1999;60(8):545-549. [pmid: 10485637].
Barnason S, Zimmerman L, Nieveen J, Hertzog M. Impact of a telehealth intervention to augment home health care on functional and recovery outcomes of elderly patients undergoing coronary artery bypass grafting. Heart & Lung. 2006;35(4):225-233. [pmid: 16863894].
Barnason S, Zimmerman L, Nieveen J, Schmaderer M, Carranza B, Reilly S. Impact of a home communication intervention for coronary artery bypass graft patients with ischemic heart failure on self-efficacy, coronary disease risk factor modification, and functioning. Heart & Lung. 2003;32(3):147-158. [pmid: 12827099].
Barrera M Jr, Glasgow RE, McKay HG, Boles SM, Feil EG. Do Internet-based support interventions change perceptions of social support?: An experimental trial of approaches for supporting diabetes self-management. American Journal of Community Psychology. 2002;30(5):637-654. [pmid: 12188054].
Block G, Wakimoto P, Metz D, Fujii ML, Feldman N, Mandel R, et al. A randomized trial of the Little by Little CD-ROM: demonstrated effectiveness in increasing fruit and vegetable intake in a low-income population. Preventing Chronic Disease. 2004;1(3):A08.
Brennan PF, Moore SM, Bjornsdottir G, Jones J, Visovsky C, Rogers M. HeartCare: an Internet-based information and support system for patient home recovery after coronary artery bypass graft (CABG) surgery. Journal of Advanced Nursing. 2001;35(5):699-708. [pmid: 11529972].
Carlbring P, Gunnarsdottir M, Hedensjo L, Andersson G, Ekselius L, Furmark T. Treatment of social phobia: randomised trial of internet-delivered cognitive-behavioural therapy with telephone support. British Journal of Psychiatry. 2007;190:123-128. [pmid: 17267928].
Cathala N, Brillat F, Mombet A, Lobel E, Prapotnich D, Alexandre L, et al. Patient followup after radical prostatectomy by Internet medical file. Journal of Urology. 2003;170(6 Pt 1):2284-2287. [pmid: 14634397].
Cavan DA, Everett J, Plougmann S, Hejlesen OK. Use of the Internet to optimize self-management of type 1 diabetes: preliminary experience with DiasNet. Journal of Telemedicine & Telecare. 2003;9(Suppl 1):S50-52. [pmid: 12952722].
Cawsey AJ, Jones RB, Pearson J. The evaluation of a personalised health information system for patients with cancer. User Modeling and User-Adapted Interaction. 2000;10(1):47-72.
Chan DS, Callahan CW, Sheets SJ, Moreno CN, Malone FJ. An Internet-based store-and-forward video home telehealth system for improving asthma outcomes in children. American Journal of Health-System Pharmacy. 2003;60(19):1976-1981. [pmid: 14531243].
Chen H, Yeh M, Chao Y. Comparing effects of auricular acupressure with and without an Internet-assisted program on smoking cessation and self-efficacy of adolescents. Journal of Alternative and Complementary Medicine. 2006;12(2):147-152.
Cho JH, Chang SA, Kwon HS, Choi YH, Ko SH, Moon SD, et al. Long-term effect of the Internet-based glucose monitoring system on HbA1c reduction and glucose stability: a 30-month follow-up study for diabetes management with a ubiquitous medical care system. Diabetes Care. 2006;29(12):2625-2631. [pmid: 17130195].
Christensen H, Griffiths KM, Jorm AF. Delivering interventions for depression by using the internet: randomised controlled trial. BMJ. 2004;328(7434):265. [pmid: 14742346].
Cross RK, Finkelstein J. Feasibility and acceptance of a home telemanagement system in patients with inflammatory bowel disease: a 6-month pilot study. Digestive Diseases & Sciences. 2007;52(2):357-364. [pmid: 17211702].
Cruz-Correia R, Fonseca J, Lima L, Araujo L, Delgado L, Castel-Branco MG, et al. Web-based or paper-based self-management tools for asthma—patients' opinions and quality of data in a randomized crossover study. Studies in Health Technology & Informatics. 2007;127:178-189. [pmid: 17901611].
Delgado DH, Costigan J, Wu R, Ross HJ. An interactive Internet site for the management of patients with congestive heart failure. Canadian Journal of Cardiology. 2003;19(12):1381-1385. [pmid: 14631472].
Durso SC, Wendel I, Letzt AM, Lefkowitz J, Kaseman DF, Seifert RF. Older adults using cellular telephones for diabetes management: a pilot study. MEDSURG Nursing. 2003;12(5):313-317. [pmid: 14608688].
Earnest MA, Ross SE, Wittevrongel L, Moore LA, Lin CT. Use of a patient-accessible electronic medical record in a practice for congestive heart failure: patient and physician experiences. Journal of the American Medical Informatics Association. 2004;11(5):410-417. [pmid: 15187074].
Estabrooks PA, Nelson CC, Xu S, King D, Bayliss EA, Gaglio B, et al. The frequency and behavioral outcomes of goal choices in the self-management of diabetes. Diabetes Educator. 2005;31(3):391-400. [pmid: 15919639].
Ewald S, vor dem Esche J, Uen S, Neikes F, Vetter H, Mengden T. Relationship between the frequency of blood pressure self-measurement and blood pressure reduction with antihypertensive therapy : results of the OLMETEL (OLMEsartan TELemonitoring blood pressure) study. Clinical Drug Investigation. 2006;26(8):439-446. [pmid: 17163276].
Ferrer-Roca O, Cardenas A, Diaz-Cardama A, Pulido P. Mobile phone text messaging in the management of diabetes. Journal of Telemedicine & Telecare. 2004a;10(5):282-285. [pmid: 15494086].
Ferrer-Roca O, Franco Burbano K, Cardenas A, Pulido P, Diaz-Cardama A. Web-based diabetes control. Journal of Telemedicine & Telecare. 2004b;10(5):277-281. [pmid: 15494085].
Finkelstein SM, Snyder M, Edin-Stibbe C, Chlan L, Prasad B, Dutta P, et al. Monitoring progress after lung transplantation from home-patient adherence. Journal of Medical Engineering & Technology. 1996;20(6):203-210. [pmid: 9029392].
Franklin VL, Waller A, Pagliari C, Greene SA. A randomized controlled trial of Sweet Talk, a text-messaging system to support young people with diabetes. Diabetic Medicine. 2006;23(12):1332-1338. [pmid: 17116184].
Frenn M, Malin S, Brown RL, Greer Y, Fox J, Greer J, et al. Changing the tide: an Internet/video exercise and low-fat diet intervention with middle-school students. Applied nursing research : ANR. 2005;18(1):13-21. [pmid: 15812731].
Gega L, Marks I, Mataix-Cols D. Computer-aided CBT self-help for anxiety and depressive disorders: experience of a London clinic and future directions. Journal of Clinical Psychology. 2004;60(2):147-157. [pmid: 14724922].
Gerber BS, Solomon MC, Shaffer TL, Quinn MT, Lipton RB. Evaluation of an internet diabetes self-management training program for adolescents and young adults. Diabetes Technology & Therapeutics. 2007;9(1):60-67. [pmid: 17316099].
Gerbert B, Berg-Smith S, Mancuso M, Caspers N, McPhee S, Null D, et al. Using innovative video doctor technology in primary care to deliver brief smoking and alcohol intervention. Health Promotion Practice. 2003;4(3):249-261. [pmid: 14610995].
Glasgow RE, Boles SM, McKay HG, Feil EG, Barrera M Jr. The D-Net diabetes self-management program: long-term implementation, outcomes, and generalization results. Preventive Medicine. 2003;36(4):410-419. [pmid: 12649049].
Glasgow RE, Toobert DJ. Brief, computer-assisted diabetes dietary self-management counseling: effects on behavior, physiologic outcomes, and quality of life. Medical Care. 2000;38(11):1062-1073. [pmid: 11078048].
Gomez EJ, Caceres C, Lopez D, Del Pozo F. A web-based self-monitoring system for people living with HIV/AIDS. Computer Methods & Programs in Biomedicine. 2002a;69(1):75-86.
Green B, et al. Effectiveness of Home Blood Pressure Monitoring, Web Communication, and Pharmacist Care on Hypertension Control. JAMA. 2008;299(24):2857-2867. [pmid: 18577730].
Guendelman S, Meade K, Benson M, Chen YQ, Samuels S. Improving asthma outcomes and self-management behaviors of inner-city children: a randomized trial of the Health Buddy interactive device and an asthma diary. Archives of Pediatrics & Adolescent Medicine. 2002;156(2):114-120. [pmid: 11814370].
Gustafson DH, Hawkins R, Boberg E, Pingree S, Serlin RE, Graziano F, et al. Impact of a patient-centered, computer-based health information/support system. American Journal of Preventive Medicine. 1999;16(1):1-9.
Gustafson DH, Hawkins R, Pingree S, McTavish F, Arora NK, Mendenhall J, et al. Effect of computer support on younger women with breast cancer. Journal of General Internal Medicine. 2001;16(7):435-445. [pmid: 11520380].
Gustafson, D. H., Hawkins, R. P., Boberg, E. W., Bricker, E., Pingree, S., & Chan, C. L. (1994). The use and impact of a computer-based support system for people living with AIDS and HIV infection. Proceedings - the Annual Symposium on Computer Applications in Medical Care, 604–608.
Gustafson DH, McTavish F, Hawkins R, Pingree S, Arora N, Mendenhall J, et al. Computer support for elderly women with breast cancer. JAMA. 1998;280(15):1305. [pmid: 9794300].
Hoch DB, Norris D, Lester JE, Marcus AD. Information exchange in an epilepsy forum on the World Wide Web. Seizure. 1999;8(1):30-34. [pmid: 10091845].
Holman RR, Smale AD, Pemberton E, Riefflin A, Nealon JL. Randomized controlled pilot trial of a hand-held patient-oriented, insulin regimen optimizer. Medical Informatics. 1996;21(4):317-326. [pmid: 9179835].
Jan RL, Wang JY, Huang MC, Tseng SM, Su HJ, Liu LF. An internet-based interactive telemonitoring system for improving childhood asthma outcomes in Taiwan. Telemedicine Journal & E-Health. 2007;13(3):257-268. [pmid: 17603828].
Japuntich SJ, Zehner ME, Smith SS, Jorenby DE, Valdez JA, Fiore MC, et al. Smoking cessation via the internet: a randomized clinical trial of an internet intervention as adjuvant treatment in a smoking cessation intervention. Nicotine & Tobacco Research. 2006;8(Suppl 1):S59-67. [pmid: 17491172].
Jones R, Pearson J, McGregor S, Cawsey AJ, Barrett A, Craig N, et al. Randomised trial of personalised computer based information for cancer patients. BMJ. 1999;319(7219):1241-1247. [pmid: 10550090].
Jones RB, Atkinson JM, Coia DA, Paterson L, Morton AR, McKenna K, et al. Randomised trial of personalised computer based information for patients with schizophrenia.[erratum appears in BMJ 2001 May 5;322(7294):1103]. BMJ. 2001;322(7290):835-840. [pmid: 11290639].
Joseph CLM, Peterson E, Havstad S, Johnson CC, Hoerauf S, Stringer S, et al. A web-based, tailored asthma management program for urban African-American high school students. American Journal of Respiratory & Critical Care Medicine. 2007;175(9):888-895. [pmid: 17290041].
Kashem A, Droogan MT, Santamore WP, Wald JW, Marble JF, Cross RC, et al. Web-based Internet telemedicine management of patients with heart failure. Telemedicine journal and e-health : the official journal of the American Telemedicine Association. 2006;12(4):439-447. [pmid: 16942416].
Kaufman DR, Patel VL, Hilliman C, Morin PC, Pevzner J, Weinstock RS, et al. Usability in the real world: assessing medical information technologies in patients' homes. Journal of Biomedical Informatics. 2003b;36(12):45-60.
Kenwright M, Marks I, Graham C, Franses A, Mataix-Cols D. Brief scheduled phone support from a clinician to enhance computer-aided self-help for obsessive-compulsive disorder: randomized controlled trial. Journal of Clinical Psychology. 2005;61(12):1499-1508. [pmid: 16173084].
Kenwright M, Marks IM. Computer-aided self-help for phobia/panic via internet at home: a pilot study. British Journal of Psychiatry. 2004;184:448-449. [pmid: 15123511].
Kim C, Kang D. Utility of a Web-based intervention for individuals with type 2 diabetes: the impact on physical activity levels and glycemic control. CIN: Computers, Informatics, Nursing. 2006a;24(6):337-345.
Kim H. A randomized controlled trial of a nurse short-message service by cellular phone for people with diabetes. International Journal of Nursing Studies. 2007;44(5):687-692. [pmid: 16618486].
Kim H, Kim N, Ahn S. Impact of a nurse short message service intervention for patients with diabetes. Journal of Nursing Care Quality. 2006b;21(3):266-271. [pmid: 16816608].
Kosma M, Cardinal BJ, McCubbin JA. A pilot study of a web-based physical activity motivational program for adults with physical disabilities. Disability and rehabilitation. 2005;27(23):1435-1442. [pmid: 16418058].
Kressig RW, Echt KV. Exercise prescribing: computer application in older adults. Gerontologist. 2002;42(2):273-277. [pmid: 11914468].
Kwon HS, Cho JH, Kim HS, Song BR, Ko SH, Lee JM, et al. Establishment of blood glucose monitoring system using the internet. Diabetes Care. 2004;27(2):478-483. [pmid: 14747232].
Labiris G, Papadopoulis G, Lentaris G, Kafentzis M, Krakakis A. Internet based counseling to remote orthopedic patients. Acta Orthopaedica Scandinavica. 2004;75(3):366-367. [pmid: 15260433].
LaFramboise LM, Todero CM, Zimmerman L, Agrawal S. Comparison of Health Buddy with traditional approaches to heart failure management. Family and Community Health. 2003;26(4):275-288. [pmid: 14528134].
Lahm EA. Software That Engages Young Children with Disabilities: A Study of Design Features. [Journal Articles Reports - Research]. Focus on Autism and Other Developmental Disabilities. 1996;11(2):115-124.
Lee TI, Yeh YT, Liu CT, Chen PL. Development and evaluation of a patient-oriented education system for diabetes management. International Journal of Medical Informatics. 2007;76(9):655-663. [pmid: 16815741].
Leu MG, Norris TE, Hummel J, Isaac M, Brogan MW. A randomized, controlled trial of an automated wireless messaging system for diabetes. Diabetes Technology & Therapeutics. 2005;7(5):710-718. discussion 719–720. [pmid: 16241873].
Levetan CS, Dawn KR, Robbins DC, Ratner RE. Impact of computer-generated personalized goals on HbA(1c). Diabetes Care. 2002;25(1):2-8. [pmid: 11772893].
Lieberman DZ. Determinants of satisfaction with an automated alcohol evaluation program. CyberPsychology & Behavior. 2003;6(6):677-682. [pmid: 14756935].
Lorig KR, Ritter PL, Laurent DD, Plant K. Internet-based chronic disease self-management: a randomized trial. Medical Care. 2006;44(11):964-971. [pmid: 17063127].
Ma C, Warren J, Phillips P, Stanek J. Empowering patients with essential information and communication support in the context of diabetes. International Journal of Medical Informatics. 2006;75(8):577-596. [pmid: 16213783].
McClure JB, Greene SM, Wiese C, Johnson KE, Alexander G, Strecher V. Interest in an online smoking cessation program and effective recruitment strategies: results from Project Quit. Journal of Medical Internet Research. 2006;8(3):e14. [pmid: 16954124].
McDaniel, A. M., Hutchison, S., Casper, G. R., Ford, R. T., Stratton, R., & Rembusch, M. (2002). Usability testing and outcomes of an interactive computer program to promote smoking cessation in low income women. Proceedings / AMIA, Annual Symposium., 509–513.
McKay HG, King D, Eakin EG, Seeley JR, Glasgow RE. The diabetes network internet-based physical activity intervention: a randomized pilot study. Diabetes Care. 2001;24(8):1328-1334. [pmid: 11473065].
McMahon GT, Gomes HE, Hickson Hohne S, Hu TM, Levine BA, Conlin PR. Web-based care management in patients with poorly controlled diabetes. Diabetes care. 2005;28(7):1624-1629. [pmid: 15983311].
McPherson AC, Glazebrook C, Forster D, James C, Smyth A. A randomized, controlled trial of an interactive educational computer package for children with asthma. Pediatrics. 2006;117(4):1046-1054. [pmid: 16585298].
McTavish, F. M., Gustafson, D. H., Owens, B. H., Wise, M., Taylor, J. O., Apantaku, F. M., et al. (1994). CHESS: An interactive computer system for women with breast cancer piloted with an under-served population. Proceedings - the Annual Symposium on Computer Applications in Medical Care, 599–603.
Meigs JB, Cagliero E, Dubey A, Murphy-Sheehy P, Gildesgame C, Chueh H, et al. A controlled trial of web-based diabetes disease management: the MGH diabetes primary care improvement project. Diabetes care. 2003;26(3):750-757. [pmid: 12610033].
Nakagawa A, Marks IM, Park JM, Bachofen M, Baer L, Dottl SL, et al. Self-treatment of obsessive-compulsive disorder guided by manual and computer-conducted telephone interview. Journal of Telemedicine & Telecare. 2000;6(1):22-26. [pmid: 10824386].
Nguyen, H. Q., Carrieri-Kohlman, V., Rankin, S. A., Slaughter, R., & Stulbarg, M. S. (2003). Pilot study of an online dyspnea self-management program for COPD. AMIA, Annual Symposium Proceedings/AMIA Symposium., 951.
Nguyen HQ, Carrieri-Kohlman V, Rankin SH, Slaughter R, Stulbarg MS. Is Internet-based support for dyspnea self-management in patients with chronic obstructive pulmonary disease possible? Results of a pilot study. Heart & Lung. 2005;34(1):51-62. [pmid: 15647734].
Noel HC, Vogel DC, Erdos JJ, Cornwall D, Levin F. Home telehealth reduces healthcare costs. Telemedicine journal and e-health : the official journal of the American Telemedicine Association. 2004;10(2):170-183. [pmid: 15319047].
Owen JE, Klapow JC, Roth DL, Shuster JL Jr, Bellis J, Meredith R, et al. Randomized pilot of a self-guided internet coping group for women with early-stage breast cancer. Annals of Behavioral Medicine. 2005;30(1):54-64. [pmid: 16097906].
Piette JD, Mah CA. The feasibility of automated voice messaging as an adjunct to diabetes outpatient care. Diabetes Care. 1997;20(1):15-21. [pmid: 9028687].
Pike KJ, Rabius V, McAlister A, Geiger A. American Cancer Society's QuitLink: randomized trial of Internet assistance. Nicotine & Tobacco Research. 2007;9(3):415-420. [pmid: 17365773].
Rami B, Popow C, Horn W, Waldhoer T, Schober E. Telemedical support to improve glycemic control in adolescents with type 1 diabetes mellitus. European Journal of Pediatrics. 2006;165(10):701-705. [pmid: 16670859].
Rasmussen LM, Phanareth K, Nolte H, Backer V. Internet-based monitoring of asthma: a long-term, randomized clinical study of 300 asthmatic subjects. Journal of Allergy & Clinical Immunology. 2005;115(6):1137-1142. [pmid: 15940125].
Reid RD, Pipe AL, Quinlan B, Oda J. Interactive voice response telephony to promote smoking cessation in patients with heart disease: a pilot study. Patient Education & Counseling. 2007;66(3):319-326. [pmid: 17336026].
Robertson L, Smith M, Castle D, Tannenbaum D. Using the Internet to enhance the treatment of depression. Australasian Psychiatry. 2006;14(4):413-417. [pmid: 17116083].
Robertson L, Smith M, Tannenbaum D. Case management and adherence to an online disease management system. Journal of Telemedicine & Telecare. 2005;11(Suppl 2):S73-75. [pmid: 16375805].
Rodgers A, Corbett T, Bramley D, Riddell T, Wills M, Lin RB, et al. Do u smoke after txt? Results of a randomised trial of smoking cessation using mobile phone text messaging. Tobacco Control. 2005;14(4):255-261. [pmid: 16046689].
Rogers MAM, Small D, Buchan DA, Butch CA, Stewart CM, Krenzer BE, et al. Home monitoring service improves mean arterial pressure in patients with essential hypertension: a randomized, controlled trial. Annals of Internal Medicine. 2001;134(11):1024-1032. I1042. [pmid: 11388815].
Ross SE, Moore LA, Earnest MA, Wittevrongel L, Lin CT. Providing a web-based online medical record with electronic communication capabilities to patients with congestive heart failure: randomized trial. Journal of Medical Internet Research. 2004;6(2):e12. [pmid: 15249261].
Rotondi AJ, Sinkule J, Spring M. An interactive Web-based intervention for persons with TBI and their families: use and evaluation by female significant others. Journal of Head Trauma Rehabilitation. 2005;20(2):173-185. [pmid: 15803040].
Ruland CM, White T, Stevens M, Fanciullo G, Khilani SM. Effects of a computerized system to support shared decision making in symptom management of cancer patients: preliminary results. Journal of the American Medical Informatics Association. 2003;10(6):573-579. [pmid: 12925545].
Runge C, Lecheler J, Horn M, Tews JT, Schaefer M. Outcomes of a Web-based patient education program for asthmatic children and adolescents. Chest. 2006;129(3):581-593. [pmid: 16537855].
Safren S. Internet paging system helps improve adherence. Counseling is combined with reminders. AIDS Alert. 2002;17(9):118-119. [pmid: 12236200].
Sciamanna CN, Harrold LR, Manocchia M, Walker NJ, Mui S. The effect of web-based, personalized, osteoarthritis quality improvement feedback on patient satisfaction with osteoarthritis care. American Journal of Medical Quality. 2005;20(3):127-137. [pmid: 15951518].
Sciamanna CN, Novak SP, Houston TK, Gramling R, Marcus BH. Visit satisfaction and tailored health behavior communications in primary care. American Journal of Preventive Medicine. 2004;26(5):426-430. [pmid: 15165659].
Shapiro JR, Reba-Harrelson L, Dymek-Valentine M, Woolson SL, Hamer RM, Bulik CM. Feasibility and acceptability of CD-ROM-based cognitive-behavioural treatment for binge-eating disorder. European Eating Disorders Review. 2007;15(3):175-184. [pmid: 17676687].
Shaw BR, Han JY, Baker T, Witherly J, Hawkins RP, McTavish F, et al. How women with breast cancer learn using interactive cancer communication systems. Health Education Research. 2007;22(1):108-119. [pmid: 16829544].
Shegog R, Bartholomew LK, Parcel GS, Sockrider MM, Masse L, Abramson SL. Impact of a computer-assisted education program on factors related to asthma self-management behavior. Journal of the American Medical Informatics Association. 2001;8(1):49-61. [pmid: 11141512].
Skeels, M. M., Kurth, A., Clausen, M., Severynen, A., & Garcia-Smith, H. (2006). CARE+ user study: usability and attitudes towards a tablet pc computer counseling tool for HIV+ men and women. AMIA, Annual Symposium Proceedings/AMIA Symposium., 729–733.
Smith L, Weinert C. Telecommunication support for rural women with diabetes. Diabetes Educator. 2000;26(4):645-655. [pmid: 11140073].
Southard BH, Southard DR, Nuckolls J. Clinical trial of an Internet-based case management system for secondary prevention of heart disease. Journal of Cardiopulmonary Rehabilitation. 2003;23(5):341-348. [pmid: 14512778].
Stinson JN, Petroz GC, Tait G, Feldman BM, Streiner D, McGrath PJ, et al. e-Ouch: usability testing of an electronic chronic pain diary for adolescents with arthritis. Clinical Journal of Pain. 2006;22(3):295-305. [pmid: 16514331].
Strecher VJ, Shiffman S, West R. Moderators and mediators of a web-based computer-tailored smoking cessation program among nicotine patch users. Nicotine & Tobacco Research. 2006;8(Suppl 1):S95-101. [pmid: 17491176].
Stuart GW, Laraia MT, Ornstein SM, Nietert PJ. An interactive voice response system to enhance antidepressant medication compliance. Topics in Health Information Management. 2003;24(1):15-20. [pmid: 12674391].
Taylor Y, Eliasson A, Andrada T, Kristo D, Howard R. The role of telemedicine in CPAP compliance for patients with obstructive sleep apnea syndrome. Sleep & Breathing. 2006;10(3):132-138. [pmid: 16565867].
Tsang MW, Mok M, Kam G, Jung M, Tang A, Chan U, et al. Improvement in diabetes control with a monitoring system based on a hand-held, touch-screen electronic diary. Journal of Telemedicine & Telecare. 2001;7(1):47-50.
Turnin MC, Beddok RH, Clottes JP, Martini PF, Abadie RG, Buisson JC, et al. Telematic expert system Diabeto. New tool for diet self-monitoring for diabetic patients. Diabetes Care. 1992;15(2):204-212. [pmid: 1547677].
van den Berg MH, Ronday HK, Peeters AJ, Voogt-van der Harst EM, Munneke M, Breedveld FC, et al. Engagement and satisfaction with an Internet-based physical activity intervention in patients with rheumatoid arthritis. Rheumatology. 2007;46(3):545-552. [pmid: 17043050].
van den Brink JL, Moorman PW, de Boer MF, Pruyn JFA, Verwoerd CDA, van Bemmel JH. Involving the patient: a prospective study on use, appreciation and effectiveness of an information system in head and neck cancer care. International Journal of Medical Informatics. 2005;74(10):839-849. [pmid: 16043392].
van der Meer V, van Stel HF, Detmar SB, Otten W, Sterk PJ, Sont JK. Internet-based self-management offers an opportunity to achieve better asthma control in adolescents. Chest. 2007;132(1):112-119. [pmid: 17400674].
Weinert C, Cudney S, Winters C. Social support in cyberspace: the next generation. CIN: Computers, Informatics, Nursing. 2005;23(1):7-15.
Wilkie DJ, Huang HY, Berry DL, Schwartz A, Lin YC, Ko NY, et al. Cancer symptom control: feasibility of a tailored, interactive computerized program for patients. Family & Community Health. 2001;24(3):48-62. [pmid: 11563944].
Williamson DA, Walden HM, White MA, York-Crowe E, Newton RL Jr, Alfonso A, et al. Two-Year Internet-Based Randomized Controlled Trial for Weight Loss in African-American Girls. Obesity. 2006;14(7):1231-1243. [pmid: 16899804].
Winzelberg AJ, Classen C, Alpers GW, Roberts H, Koopman C, Adams RE, et al. Evaluation of an internet support group for women with primary breast cancer. Cancer. 2003;97(5):1164-1173. [pmid: 12599221].
Woodruff SI, Edwards CC, Conway TL, Elliott SP. Pilot test of an Internet virtual world chat room for rural teen smokers. Journal of Adolescent Health. 2001;29(4):239-243. [pmid: 11587907].
Yon BA, Johnson RK, Harvey-Berino J, Gold BC, Howard AB. Personal digital assistants are comparable to traditional diaries for dietary self-monitoring during a weight loss program. Journal of Behavioral Medicine. 2007;30(2):165-175. [pmid: 17216341].
Zabinski MF, Wilfley DE, Pung MA, Winzelberg AJ, Eldredge K, Taylor CB. An interactive internet-based intervention for women at risk of eating disorders: a pilot study. International Journal of Eating Disorders. 2001;30(2):129-137. [pmid: 11449446].
Zimmerman L, Barnason S, Nieveen J, Schmaderer M. Symptom management intervention in elderly coronary artery bypass graft patients. Outcomes Management. 2004;8(1):5-12. [pmid: 14740578].