# Appendix G. Peer Reviewers

Majd Alwan President of CAST (Center for Aging Services Technologies), Washington DC

Cheryl Austein-Casnoff Office of Health Information Technology, (HRSA), Rockville, Maryland

Joyce Dubow Senior Advisor AARP Office of Policy and Strategy, Washington DC

Daryle Gardner-Bonneau, MD Human Factors and Ergonomics Society, Portage, Mississippi

Margaret Giannini, MD, FAAP Director, Office on Disability at HHS, Washington DC

Linda Golodner, BA President and CEO of the National Consumer's League and chairs the Alliance Against Fraud in Telemarketing and electronic Commerce and serves on the Board of the National Council on Patient Information and Education, the National Patient Safety Foundation, the Patient Safety Institute and the American National Standards Institute, Washington DC

Donald Grantt Director, Evidence-Based Disease and Disability Prevention Program U.S. Administration on Aging Office of Planning and Policy Development, Washington DC

Rita Kukafka, DrPH, MA Assistant Professor of Sociomedical Sciences, Mailman School of Public Health and Assistant Professor of Biomedical Informatics, College of Physicians and Surgeons, New York City, New York