# Appendix F. Quality Assessment Criteria

Study Design | United States Preventive Services Task Force quality rating criteria^1^
Systematic reviews and meta-analyses | - Comprehensiveness of sources considered/search strategy used; - Standard appraisal of included studies; - Validity of conclusions; - Recency and relevance are especially important for systematic reviews
Case-control studies | - Accurate ascertainment of cases; - Nonbiased selection of cases/controls with exclusion criteria applied equally to both; - Response rate; - Diagnostic testing procedures applied equally to each group; - Measurement of exposure accurate and applied equally to each group; - Appropriate attention to potential confounding variables
Randomized controlled trials (RCTs) | - Initial assembly of comparable groups employs adequate randomization, including first concealment and whether potential confounders were distributed equally among groups; - Maintenance of comparable groups (includes attrition, crossovers, adherence, contamination); - Important differential loss to followup or overall high loss to followup; - Measurements are equal, reliable, and valid (includes masking of outcome assessment); - Clear definition of the interventions; - All important outcomes considered
Cohort studies | - Initial assembly of comparable groups employs consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts; - Maintenance of comparable groups (includes attrition, crossovers, adherence, contamination); - Important differential loss to followup or overall high loss to followup; - Measurements are equal, reliable, and valid (includes masking of outcome assessment); - Clear definition of the interventions; - All important outcomes considered
Diagnostic accuracy studies | - Screening test relevant, available for primary care, adequately described; - Study uses a credible reference standard, performed regardless of test results; - Reference standard interpreted independently of screening test; - Handles indeterminate result in a reasonable manner; - Spectrum of patients included in study; - Sample size; - Administration of reliable screening test

## CRD's Guidance for those Carrying Out or Commissioning Reviews

Quality criteria for assessment of experimental studies^2^

1 Was the assignment to the treatment groups really random?
  - Adequate approaches to sequence generation
    - Computer-generated random numbers
    - Random numbers tables
  - Inadequate approaches to sequence generation
    - Use of alternation, case record numbers, birth dates or week days
2 Was the treatment allocation concealed?
  - Adequate approaches to concealment of randomization
    - Centralized or pharmacy-controlled randomization
    - Serially-numbered identical containers
    - On-site computer based system with a randomization sequence that is not
  - readable until allocation
    - Other approaches with robust methods to prevent foreknowledge of the allocation
  - sequence to clinicians and patients
  - Inadequate approaches to concealment of randomization
    - Use of alternation, case record numbers, birth dates or week days
    - Open random numbers lists
    - Serially numbered envelopes (even sealed opaque envelopes can be subject to manipulation)
3 Were the groups similar at baseline in terms of prognostic factors?
4 Were the eligibility criteria specified?
5 Were outcome assessors blinded to the treatment allocation?
6 Was the care provider blinded?
7 Was the patient blinded?
8 Were the point estimates and measure of variability presented for the primary outcome measure?
9 Did the analyses include an intention to treat analysis

Some quality criteria for assessment of observational studies

Cohort studies

- Is there sufficient description of the groups and the distribution of prognostic factors?
- Are the groups assembled at a similar point in their disease progression?
- Is the intervention/treatment reliably ascertained?
- Were the groups comparable on all important confounding factors?
- Was there adequate adjustment for the effects of these confounding variables?
- Was a dose-response relationship between intervention and outcome demonstrated?
- Was outcome assessment blind to exposure status?
- Was follow-up long enough for the outcomes to occur?
- What proportion of the cohort was followed-up?
- Were drop-out rates and reasons for drop-out similar across intervention and unexposed groups?

Case-control studies

- Is the case definition explicit?
- Has the disease state of the cases been reliably assessed and validated?
- Were the controls randomly selected from the source of population of the cases?
- How comparable are the cases and controls with respect to potential confounding factors?
- Were interventions and other exposures assessed in the same way for cases and controls?
- How was the response rate defined?
- Were the non-response rates and reasons for non-response the same in both groups?
- Is it possible that over-matching has occurred in that cases and controls were matched on factors related to exposure?
- Was an appropriate statistical analysis used (matched or unmatched)?

Case series

- Is the study based on a representative sample selected from a relevant population?
- Are the criteria for inclusion explicit?
- Did all individuals enter the survey at a similar point in their disease progression?
- Was follow-up long enough for important events to occur?
- Were outcomes assessed using objective criteria or was blinding used?
- If comparisons of sub-series are being made, was there sufficient description of the series and the distribution of prognostic factors?

Critical Appraisal Skills Programme (CASP) ^3^

Making sense of evidence, 10 questions to help you make sense of qualitative research

Currently awaiting approval to re-publish criteria here.

### References

1 Harris RP, Hefland M, Woolf SH, et al. Methods Work Group, Third US Preventive Services Task Force. Current methods of the US Preventive Services Task Force: a review of the process. American Journal of Preventive Medicine. 2001;20(3 Suppl):21-35.
2 Khan K, ter Riet G, Popay J, Nixon J, Kleijnen J. Undertaking Systematic Reviews of Research on Effectiveness: Stage II: Conducting the Review. York: University of York; 2001.
3 Critical Appraisal Skills Programme. 10 questions to help you make sense of qualitative research: Milton Keynes Primary Care Trust; 2002.