# Appendix E. Excluded Studies List

[underlined: EXCLUDE CODE E:]

E: Other

E1: Wrong Population

E2: No Data

E3: Wrong Intervention/Technology

## References

1 Use the Internet to reach more patients with your demand management programs. Healthcare Demand & Disease Management, 1997. 3(5): p. 75–7. Exclude Code: E1
2 Elderly patients embrace touch-screen technology. Telemedicine & Virtual Reality, 1998. 3(12): p. 144. Exclude Code: E3
3 Online advice on problem drinking could fulfill unmet need: success of services depends on proper targeting. Alcoholism & Drug Abuse Weekly, 2006. 18(13): p. 5–7. Exclude Code: E2
4 Telehealth helps hospital cut readmissions by 75%. Healthcare Benchmarks & Quality Improvement, 2007. 14(8): p. 92–4. Exclude Code: E2
5 Abroms LC, et al. The STRENGTH Ezine: an application of e-mail for health promotion in adolescent girls. American Journal of Health Promotion. 2004;19(1):28-32. Exclude Code: E1. [pmid: 15460098].
6 Adams, W.G., et al., TLC-Asthma: an integrated information system for patient-centered monitoring, case management, and point-of-care decision support. AMIA, 2003. Annual Symposium Proceedings/AMIA Symposium.: p. 1–5. Exclude Code: E
7 Adamsen L, Rasmussen JM. Exploring and encouraging through social interaction: a qualitative study of nurses' participation in self-help groups for cancer patients. Cancer Nursing. 2003;26(1):28-36. Exclude Code: E3. [pmid: 12556710].
8 Adkins JW, et al. Home-based behavioral health intervention: Use of a telehealth model to address poor adherence to type-1 diabetes medical regimens. Telemedicine Journal & E-Health. 2006;12(3):370-2. Exclude Code: E3. [pmid: 16796506].
9 Adler KG. Web portals in primary care: an evaluation of patient readiness and willingness to pay for online services. Journal of Medical Internet Research. 2006;8(4):e26. Exclude Code: E3. [pmid: 17213045].
10 Agnew T. User friendly at any age. Nursing Older People. 2006;18(8):8-9. Exclude Code: E2.
11 Agre P. Interactive computer technology. Cancer Practice. 1994;2(1):74-6. Exclude Code: E. [pmid: 8055010].
12 Agrell H, Dahlberg S, Jerant AF. Patients' perceptions regarding home telecare. Telemedicine Journal & E-Health. 2000;6(4):409-15. Exclude Code: E3. [pmid: 11242549].
13 Ahmed M, Bayog F, Boisvert CM. Computer-facilitated therapy for inpatients with schizophrenia. Psychiatric Services. 1997;48(10):1334-5. Exclude Code: E1. [pmid: 9323756].
14 Ahring KK, et al. Telephone modem access improves diabetes control in those with insulin-requiring diabetes. Diabetes Care. 1992;15(8):971-5. Exclude Code: E3. [pmid: 1505329].
15 Alemi F, et al. Electronic self-help and support groups. Medical Care. 1996;34(10 Suppl):OS32-44. Exclude Code: E. [pmid: 8843935].
16 Alemi F, et al. Automated monitoring of outcomes: application to treatment of drug abuse. Medical Decision Making. 1994;14(2):180-7. Exclude Code: E3. [pmid: 8028471].
17 Alemi F, et al. Educating patients at home. Community Health Rap. Medical Care. 1996;34(10 Suppl):OS21-31. Exclude Code: E3. [pmid: 8843934].
18 Allen A, Hayes J. Patient satisfaction with telemedicine in a rural clinic. American Journal of Public Health. 1994;84(10):1693. Exclude Code: E3. [pmid: 7943501].
19 Allen DN, et al. Teaching memory strategies to persons with multiple sclerosis. Journal of Rehabilitation Research & Development. 1998;35(4):405-10. Exclude Code: E3. [pmid: 10220218].
20 Alonso A. A new model for home care for COPD. Studies in Health Technology & Informatics. 2004;103:368-73. Exclude Code: E3. [pmid: 15747942].
21 Als AB. The desk-top computer as a magic box: patterns of behaviour connected with the desk-top computer; GPs' and patients' perceptions. Family Practice. 1997;14(1):17-23. Exclude Code: E3. [pmid: 9061339].
22 Alterman AI, Baughman TG. Videotape versus computer interactive education in alcoholic and nonalcoholic controls. Alcoholism: Clinical & Experimental Research. 1991;15(1):39-44. Exclude Code: E3.
23 Alwan M, et al. Impact of monitoring technology in assisted living: outcome pilot. IEEE Transactions on Information Technology in Biomedicine. 2006;10(1):192-8. Exclude Code: E3. [pmid: 16445264].
24 Anderson ES, et al. A computerized social cognitive intervention for nutrition behavior: direct and mediated effects on fat, fiber, fruits, and vegetables, self-efficacy, and outcome expectations among food shoppers. Annals of Behavioral Medicine. 2001;23(2):88-100. Exclude Code: E1. [pmid: 11394559].
25 Andreassen HK, et al. Patients who use e-mediated communication with their doctor: new constructions of trust in the patient-doctor relationship. Qualitative health research. 2006;16(2):238-48. Exclude Code: E1. [pmid: 16394212].
26 Andrews G. ClimateGP - web based patient education. Australian Family Physician. 2007;36(5):371-2. Exclude Code: E3. [pmid: 17492076].
27 Anhoj J, Moldrup C. Feasibility of collecting diary data from asthma patients through mobile phones and SMS (short message service): response rate analysis and focus group evaluation from a pilot study. Journal of Medical Internet Research. 2004;6(4):e42. Exclude Code: E. [pmid: 15631966].
28 Anogianakis G, Maglavera S, Pomportsis A. ATTRACT—applications in telemedicine taking rapid advantage of cable television network evolution. Studies in Health Technology & Informatics. 1998;50:60-6. Exclude Code: E3. [pmid: 10180587].
29 Ansari M, et al. Improving guideline adherence: a randomized trial evaluating strategies to increase beta-blocker use in heart failure. Circulation. 2003;107(22):2799-804. Exclude Code: E3. [pmid: 12756157].
30 Aoki N, et al. Edutainment tools for initial education of type-1 diabetes mellitus: initial diabetes education with fun. Medinfo. 2004;11(Pt 2):855-9. Exclude Code: E3.
31 Aoki N, et al. INSULOT: a cellular phone-based edutainment learning tool for children with type 1 diabetes. Diabetes Care. 2005;28(3):760. Exclude Code: E3. [pmid: 15735232].
32 Aoki N, et al. u-SHARE: web-based decision support/risk communication tool for healthcare consumers with unruptured intracranial aneurysms. Medinfo. 2007;12(Pt 2):1012-6. Exclude Code: E3.
33 Artinian NT, et al. Effects of nurse-managed telemonitoring on blood pressure at 12-month follow-up among urban African Americans. Nursing research. 2007;56(5):312-22. Exclude Code: E3. [pmid: 17846552].
34 Artinian NT, et al. Effects of nurse-managed telemonitoring on blood pressure at 12-month follow-up among urban African Americans. Nursing Research. 2007;56(5):312-22. Exclude Code: E3. [pmid: 17846552].
35 Artinian NT, et al. Effects of nurse-managed telemonitoring on blood pressure at 12-month follow-up among urban African Americans. Nursing Research. 2007;56(5):312-22. Exclude Code: E3. [pmid: 17846552].
36 Artinian NT, Washington OG, Templin TN. Effects of home telemonitoring and community-based monitoring on blood pressure control in urban African Americans: a pilot study. Heart & Lung. 2001;30(3):191-9. Exclude Code: E3. [pmid: 11343005].
37 Atkinson NL, et al. Assessment of the nutrition and physical activity education needs of low-income, rural mothers: can technology play a role?. Journal of Community Health. 2007;32(4):245-67. Exclude Code: E3. [pmid: 17696049].
38 Baba M, Seckin D, Kapdali S. A comparison of teledermatology using store-and-forward methodology alone, and in combination with Web camera videoconferencing. Journal of Telemedicine & Telecare. 2005;11(7):354-60. Exclude Code: E3. [pmid: 16238837].
39 Baehring TU, et al. Using the World Wide Web—a new approach to risk identification of diabetes mellitus. International Journal of Medical Informatics. 1997;46(1):31-9. Exclude Code: E3. [pmid: 9476153].
40 Baker L, et al. Use of the Internet and e-mail for health care information: results from a national survey. JAMA. 2003;289(18):2400-6. Exclude Code: E1. [pmid: 12746364].
41 Bakken S, et al. Development, validation, and use of English and Spanish versions of the telemedicine satisfaction and usefulness questionnaire. Journal of the American Medical Informatics Association. 2006;13(6):660-7. Exclude Code: E3. [pmid: 16929036].
42 Balas EA, et al. Electronic communication with patients. Evaluation of distance medicine technology. JAMA. 1997;278(2):152-9. Exclude Code: E3. [pmid: 9214532].
43 Baranowski T, et al. The Fun, Food, and Fitness Project (FFFP): the Baylor GEMS pilot study. Ethnicity & disease. 2003;13(1 Suppl 1):S30-9. Exclude Code: E3. [pmid: 12713209].
44 Barber JG. Computer-assisted drug prevention. Journal of Substance Abuse Treatment. 1990;7(2):125-31. Exclude Code: E2. [pmid: 2201790].
45 Barnes N, et al. Liverpool Telecare Pilot: case studies. Informatics in Primary Care. 2006;14(3):197-202. Exclude Code: E3.
46 Barnett TE, et al. The effectiveness of a care coordination home telehealth program for veterans with diabetes mellitus: a 2-year follow-up. American Journal of Managed Care. 2006;12(8):467-474. Exclude Code: E3. [pmid: 16886889].
47 Baron J, et al. Effect of assessment method on the discrepancy between judgments of health disorders people have and do not have: a web study. Medical Decision Making. 2003;23(5):422-34. Exclude Code: E1. [pmid: 14570300].
48 Bartholomew L, et al. Watch, Discover, Think, and Act: Evaluation of computer-assisted instruction to improve asthma self-management in inner-city children. Patient Education and Counseling. 2000;39(23):269-280. Exclude Code: E2. [pmid: 11040726].
49 Bartholomew LK, et al. Watch, Discover, Think, and Act: evaluation of computer-assisted instruction to improve asthma self-management in inner-city children. Patient Education & Counseling. 2000;39(23):269-80. Exclude Code: E2. [pmid: 11040726].
50 Bartholomew LK, et al. Watch, Discover, Think, and Act: a model for patient education program development. Patient Education & Counseling. 2000;39(23):253-68. Exclude Code: E2. [pmid: 11040725].
51 Basch E, et al. Patient online self-reporting of toxicity symptoms during chemotherapy. Journal of Clinical Oncology. 2005;23(15):3552-61. Exclude Code: E3. [pmid: 15908666].
52 Basch E, et al. Evaluation of an online platform for cancer patient self-reporting of chemotherapy toxicities. Journal of the American Medical Informatics Association. 2007;14(3):264-8. Exclude Code: E3. [pmid: 17329732].
53 Bastian LA, et al. Evaluating participants' use of a hormone replacement therapy decision-making intervention. Patient Education & Counseling. 2002;48(3):283-91. Exclude Code: E3. [pmid: 12477613].
54 Baum LS. Internet parent support groups for primary caregivers of a child with special health care needs. Pediatric Nursing. 30(5):381-8. Exclude Code: E3. [pmid: 15587531].
55 Beale IL, et al. Improvement in cancer-related knowledge following use of a psychoeducational video game for adolescents and young adults with cancer. Journal of Adolescent Health. 2007;41(3):263-70. Exclude Code: E3. [pmid: 17707296].
56 Beaudin JS, Intille SS, Morris ME. To track or not to track: user reactions to concepts in longitudinal health monitoring. Journal of Medical Internet Research. 2006;8(4):e29. Exclude Code: E1. [pmid: 17236264].
57 Bechtel-Blackwell DA. Computer-assisted self-interview and nutrition education in pregnant teens. Clinical Nursing Research. 2002;11(4):450-62. Exclude Code: E1. [pmid: 12413116].
58 Beck H, et al. Computer skills in patients with movement disorders. Parkinsonism & Related Disorders. 2005;11(7):421-6. Exclude Code: E3. [pmid: 16154795].
59 Benatar D, et al. Outcomes of chronic heart failure. Archives of internal medicine. 2003;163(3):347-52. Exclude Code: E3. [pmid: 12578516].
60 Bendixen RM, Horn K, Levy C. Using telerehabilitation to support elders with chronic illness in their homes. Topics in Geriatric Rehabilitation. 2007;23(1):47-51. Exclude Code: E3.
61 Bensink M, et al. Investigating the cost-effectiveness of videotelephone based support for newly diagnosed paediatric oncology patients and their families: design of a randomised controlled trial. BMC Health Services Research. 2007;7:38. Exclude Code: E3. [pmid: 17335589].
62 Berry DL, et al. Actual use and perceived usefulness of a web-based, decision support program for men with prostate cancer. Studies in Health Technology & Informatics. 2006;122:781-2. Exclude Code: E3. [pmid: 17102377].
63 Bielli E, et al. A Wireless Health Outcomes Monitoring System (WHOMS): development and field testing with cancer patients using mobile phones. BMC Medical Informatics & Decision Making. 2004;4:7. Exclude Code: E3. [pmid: 15196308].
64 Biermann E, et al. Are there time and cost savings by using telemanagement for patients on intensified insulin therapy? A randomised, controlled trial. Computer Methods & Programs in Biomedicine. 2002;69(2):137-46. Exclude Code: E3. [pmid: 12100793].
65 Bik-Multanowski M, et al. Use of handheld computers for assessment of prefrontal cortex function in patients with phenylketonuria. Molecular Genetics & Metabolism. 2005;86(Suppl 1):S142-4. Exclude Code: E3. [pmid: 16165388].
66 Birkmann C, Dumitru RC, Prokosch HU. Evaluation of health-related Internet use in Germany. Methods of Information in Medicine. 2006;45(4):367-76. Exclude Code: E1. [pmid: 16964351].
67 Block G, et al. An interactive CD-ROM for nutrition screening and counseling. American Journal of Public Health. 2000;90(5):781-5. Exclude Code: E. [pmid: 10800430].
68 Bock B, et al. Acceptability of computer assessments among ethnically diverse, low-income smokers. American Journal of Health Promotion. 1999;13(5):299-304. Exclude Code: E3. [pmid: 10538645].
69 Boisen E, et al. Copability, coping, and learning as focal concepts in the evaluation of computerised diabetes disease management. International Journal of Medical Informatics. 2003;70(23):353-63. Exclude Code: E2. [pmid: 12909188].
70 Boissy P, Jacobs K, Roy SH. Usability of a barcode scanning system as a means of data entry on a PDA for self-report health outcome questionnaires: a pilot study in individuals over 60 years of age. BMC Medical Informatics & Decision Making. 2006;6:42. Exclude Code: E3. [pmid: 17184533].
71 Bosworth HB, et al. Hypertension Intervention Nurse Telemedicine Study (HINTS): testing a multifactorial tailored behavioral/educational and a medication management intervention for blood pressure control. American Heart Journal. 2007;153(6):918-24. Exclude Code: E3. [pmid: 17540191].
72 Bowen AM, Horvath K, Williams ML. A randomized control trial of Internet-delivered HIV prevention targeting rural MSM. Health Education Research. 2007;22(1):120-7. Exclude Code: E3. [pmid: 16849391].
73 Bratan T, et al. Evaluation of the practical feasibility and acceptability of home monitoring in residential homes. Journal of Telemedicine & Telecare. 2005;11(Suppl 1):29-31. Exclude Code: E3.
74 Brenner B. Is the provision of laboratory results via the Internet acceptable to patients? A survey of private patients in a large, specialist gynaecology practice. New Zealand Medical Journal. 2003;116(1187):U711. Exclude Code: E1. [pmid: 14752539].
75 Brown CL, Tangsinmankong N, Emmanuel PJ. Improving care of HIV-infected patients in the outpatient setting with patient data flow sheets. Journal of the Association of Nurses in AIDS Care. 2002;13(4):58-63. Exclude Code: E3. [pmid: 12149885].
76 Brown SJ, et al. Educational video game for juvenile diabetes: results of a controlled trial. Medical Informatics. 1997;22(1):77-89. Exclude Code: E3. [pmid: 9183781].
77 Bruning Brown J, et al. An evaluation of an Internet-delivered eating disorder prevention program for adolescents and their parents. Journal of Adolescent Health. 2004;35(4):290-6. Exclude Code: E1. [pmid: 15450542].
78 Bulmer PJ, et al. A randomized trial comparing the effectiveness and preference of a touch-screen computer system with a leaflet for providing women with information on urinary symptoms suggestive of detrusor instability. BJU International. 2001;88(6):532-5. Exclude Code: E3. [pmid: 11678745].
79 Burkhart PV, et al. Testing an intervention to promote children's adherence to asthma self-management. Journal of Nursing Scholarship. 2007;39(2):133-40. Exclude Code: E. [pmid: 17535313].
80 Bush N, et al. Development, feasibility and compliance of a web-based system for very frequent QOL and symptom home self-assessment after hematopoietic stem cell transplantation. Quality of Life Research. 2005;14(1):77-93. Exclude Code: E3. [pmid: 15789943].
81 Butler SF, et al. Working it out: development and testing of a multimedia, vocational education program. Substance Use & Misuse. 2004;39(1314):2525-58. Exclude Code: E3. [pmid: 15603013].
82 Campbell E, et al. Encouraging underscreened women to have cervical cancer screening: the effectiveness of a computer strategy. Preventive Medicine. 1997;26(6):801-7. Exclude Code: E1. [pmid: 9388791].
83 Campbell MK, et al. Randomized trial of a tailored nutrition education CD-ROM program for women receiving food assistance. Journal of Nutrition Education and Behavior. 2004;36(2):58-66. Exclude Code: E3. [pmid: 15068753].
84 Carlbring P, et al. Remote treatment of panic disorder: a randomized trial of internet-based cognitive behavior therapy supplemented with telephone calls. The American journal of psychiatry. 2006;163(12):2119-25. Exclude Code: E3. [pmid: 17151163].
85 Carlbring P, et al. Treatment of social phobia: randomised trial of internet-delivered cognitive-behavioural therapy with telephone support. British Journal of Psychiatry. 2007;190:123-8. Exclude Code: E3. [pmid: 17267928].
86 Carlbring P, et al. Treatment of panic disorder via the Internet: A randomized trial of a self-help program. Behavior Therapy. 2001;32(4):751-764. Exclude Code: E3.
87 Carpenter KM, et al. Teaching brief interventions for smoking cessation via an interactive computer-based tutorial. Journal of Health Psychology. 2003;8(1):149-60. Exclude Code: E3.
88 Chen HH, Yeh ML. Developing and evaluating a smoking cessation program combined with an Internet-assisted instruction program for adolescents with smoking. Patient education and counseling. 2006;61(3):411-8. Exclude Code: E. [pmid: 16125357].
89 Cherry JC, et al. Diabetes disease management program for an indigent population empowered by telemedicine technology. Diabetes Technology & Therapeutics. 2002;4(6):783-91. Exclude Code: E3. [pmid: 12685802].
90 Chou M, et al. Exploring the self-learning experiences of patients with depression participating in a multimedia education program. Journal of Nursing Research. 2004;12(4):297-305. Exclude Code: E3. [pmid: 15619180].
91 Christensen DB, et al. Assessing compliance to antihypertensive medications using computer-based pharmacy records. Medical Care. 1997;35(11):1164-70. Exclude Code: E3. [pmid: 9366895].
92 Christenson MA. Assessing an elder's need for assistance: one technological tool. Generations. 1995;19(1):54-55. Exclude Code: E2.
93 Chung M, Akahoshi M. Reducing home nursing visit costs using a remote access infusion pump system. Journal of Intravenous Nursing. 1999;22(6):309-14. Exclude Code: E3. [pmid: 10865597].
94 Clemensen J, Larsen SB, Ejskjaer N. Telemedical treatment at home of diabetic foot ulcers. Journal of Telemedicine & Telecare. 2005;11(Suppl 2):S14-6. Exclude Code: E3. [pmid: 16375785].
95 Crosbie JH, et al. Virtual reality in the rehabilitation of the upper limb after stroke: the user's perspective. Cyberpsychology & Behavior. 2006;9(2):137-41. Exclude Code: E3. [pmid: 16640466].
96 Cunningham JA, Humphreys K, Koski-Jannes A. Providing personalized assessment feedback for problem drinking on the Internet: a pilot project. Journal of Studies on Alcohol. 2000;61(6):794-8. Exclude Code: E1. [pmid: 11188484].
97 Cunningham JA, et al. Internet and paper self-help materials for problem drinking: is there an additive effect?. Addictive Behaviors. 2005;30(8):1517-23. Exclude Code: E1. [pmid: 15893433].
98 Cunningham JA, Selby P, van Mierlo T. Integrated online services for smokers and drinkers? Use of the check your drinking assessment screener by participants of the Stop Smoking Center. Nicotine & Tobacco Research. 2006;8(Suppl 1):S21-5. Exclude Code: E2. [pmid: 17491167].
99 Cytryn KN, Patel VL. Reasoning about diabetes and its relationship to the use of telecommunication technology by patients and physicians. International Journal of Medical Informatics. 1998;51(23):137-51. Exclude Code: E. [pmid: 9794330].
100 Dale J, Connor S, Tolley K. An evaluation of the west Surrey telemedicine monitoring project. Journal of Telemedicine & Telecare. 2003;9(Suppl 1):S39-41. Exclude Code: E3.
101 Datto CJ, et al. The pilot study of a telephone disease management program for depression. General Hospital Psychiatry. 2003;25(3):169-77. Exclude Code: E3. [pmid: 12748029].
102 De Bourdeaudhuij I, et al. Evaluation of an interactive computer-tailored nutrition intervention in a real-life setting. Annals of Behavioral Medicine. 2007;33(1):39-48. Exclude Code: E. [pmid: 17291169].
103 de Lusignan S, et al. A pilot study of radiotelemetry for continuous cardiopulmonary monitoring of patients at home. Journal of Telemedicine & Telecare. 2000;6(Suppl 1):S119-22. Exclude Code: E3. [pmid: 10793994].
104 DeLenardo C. Web-based tools steer patient-focused care: portal technology empowers patients to track and improve outcomes. Holistic Nursing Practice. 2005;19(2):90-2. Exclude Code: E2.
105 Delgado M, Santiago J. HIV/AIDS in a Puerto Rican/Dominican community: a collaborative project with a botanical shop. Social Work. 1998;43(2):183-6. Exclude Code: E3. [pmid: 9528392].
106 Delic D, Polasek O, Kern J. Internet health-information seekers in Croatia—who, what, and why?. Medical Informatics & the Internet in Medicine. 2006;31(4):267-73. Exclude Code: E3. [pmid: 17135059].
107 DePalma A. Prostate Cancer Shared Decision: a CD-ROM educational and decision-assisting tool for men with prostate cancer. Seminars in Urologic Oncology. 2000;18(3):178-81. Exclude Code: E2. [pmid: 10975488].
108 Diamond BJ, et al. Telerehabilitation, cognition and user-accessibility. Neurorehabilitation. 2003;18(2):171-7. Exclude Code: E3. [pmid: 12867679].
109 Diefenbach MA, Butz BP. A multimedia interactive education system for prostate cancer patients: development and preliminary evaluation. Journal of Medical Internet Research. 2004;6(1):e3. Exclude Code: E3. [pmid: 15111269].
110 Dobscha SK, et al. Measuring depression and pain with home health monitors. Telemedicine Journal & E-Health. 2006;12(6):702-6. Exclude Code: E3. [pmid: 17250493].
111 Donald S, et al. Evaluation of use of cellphones to aid compliance with drug therapy for HIV patients. AIDS Care. 2007;19(5):605-7. Exclude Code: E. [pmid: 17505920].
112 Dragone MA, et al. Development and evaluation of an interactive CD-ROM for children with leukemia and their families. Patient Education & Counseling. 2002;46(4):297-307. Exclude Code: E3. [pmid: 11932129].
113 Duff A, et al. Betterland: an interactive cd-rom guide for children with cystic fibrosis. Paediatric Nursing. 2006;18(7):30-3. Exclude Code: E2. [pmid: 16986754].
114 Dunbar PJ, et al. A two-way messaging system to enhance antiretroviral adherence. Journal of the American Medical Informatics Association. 2003;10(1):11-5. Exclude Code: E3. [pmid: 12509353].
115 Edworthy SM, Devins GM. Improving medication adherence through patient education distinguishing between appropriate and inappropriate utilization. Patient Education Study Group. Journal of Rheumatology. 1999;26(8):1793-801. Exclude Code: E3. [pmid: 10451079].
116 Eisermann U, Haase I, Kladny B. Computer-aided multimedia training in orthopedic rehabilitation. American Journal of Physical Medicine & Rehabilitation. 2004;83(9):670-80. Exclude Code: E3. [pmid: 15314531].
117 Emery J, et al. The GRAIDS Trial: a cluster randomised controlled trial of computer decision support for the management of familial cancer risk in primary care. British Journal of Cancer. 2007;97(4):486-93. Exclude Code: E1. [pmid: 17700548].
118 Engelbrecht R, et al. DIABCARD—an application of a portable medical record for persons with diabetes. Medical Informatics. 1996;21(4):273-82. Exclude Code: E3. [pmid: 9179832].
119 Eriksson J, Ek A, Johansson G. Design and evaluation of a software prototype for participatory planning of environmental adaptations. IEEE Transactions on Rehabilitation Engineering. 2000;8(1):94-106. Exclude Code: E3. [pmid: 10779113].
120 Finkel S, et al. E-care: a telecommunications technology intervention for family caregivers of dementia patients. American Journal of Geriatric Psychiatry. 2007;15(5):443-448. Exclude Code: E1. [pmid: 17463195].
121 Finkelstein J, Cabrera MR, Hripcsak G. Internet-based home asthma telemonitoring: can patients handle the technology?. Chest. 2000;117(1):148-55. Exclude Code: E. [pmid: 10631213].
122 Fortney JC, et al. Design and implementation of the telemedicine-enhanced antidepressant management study. General hospital psychiatry. 2006;28(1):18-26. Exclude Code: E3. [pmid: 16377361].
123 Franck LS, Jones M. Computer-taught coping techniques for venepuncture: preliminary findings from usability testing with children, parents and staff. Journal of Child Health Care. 2003;7(1):41-54. Exclude Code: E3. [pmid: 12665340].
124 Friedman RH, et al. A telecommunications system to manage patients with chronic disease. Medinfo. 1998;9(Pt 2):1330-4. Exclude Code: E2.
125 Frosch DL, Kaplan RM, Felitti VJ. A randomized controlled trial comparing internet and video to facilitate patient education for men considering the prostate specific antigen test. Journal of General Internal Medicine. 2003;18(10):781-7. Exclude Code: E3. [pmid: 14521639].
126 Gerber, B.S., et al., Implementation of computer multimedia for diabetes prevention in African-American women. AMIA, 2005. Annual Symposium Proceedings/AMIA Symposium.: p. 962. Exclude Code: E3
127 Giallauria F, et al. Efficacy of telecardiology in improving the results of cardiac rehabilitation after acute myocardial infarction. Monaldi Archives for Chest Disease. 2006;66(1):8-12. Exclude Code: E3. [pmid: 17125041].
128 Glasgow RE, et al. Long-term effects and costs of brief behavioural dietary intervention for patients with diabetes delivered from the medical office. Patient Education & Counseling. 1997;32(3):175-84. Exclude Code: E3. [pmid: 9423499].
129 Glazebrook C, et al. Impact of a multimedia intervention “Skinsafe” on patients' knowledge and protective behaviors. Preventive Medicine. 2006;42(6):449-54. Exclude Code: E1. [pmid: 16580059].
130 Goldfield GS, Boachie A. Delivery of family therapy in the treatment of anorexia nervosa using telehealth. Telemedicine Journal & E-Health. 2003;9(1):111-4. Exclude Code: E3. [pmid: 12699614].
131 Gomez EJ, et al. Telemedicine as a tool for intensive management of diabetes: the DIABTel experience. Computer Methods & Programs in Biomedicine. 2002;69(2):163-77. Exclude Code: E3. [pmid: 12100795].
132 Graham AL, et al. Characteristics of smokers reached and recruited to an internet smoking cessation trial: a case of denominators. Nicotine & Tobacco Research. 2006;8(Suppl 1):S43-8. Exclude Code: E3. [pmid: 17491170].
133 Grant RW, et al. Design and implementation of a web-based patient portal linked to an ambulatory care electronic health record: patient gateway for diabetes collaborative care. Diabetes Technology & Therapeutics. 2006;8(5):576-86. Exclude Code: E2. [pmid: 17037972].
134 Gray, J., et al., Baby CareLink: development and implementation of a WWW-based system for neonatal home telemedicine. Proceedings / AMIA, 1998. Annual Symposium.: p. 351–5. Exclude Code: E1
135 Gray JE, et al. Baby CareLink: using the internet and telemedicine to improve care for high-risk infants. Pediatrics. 2000;106(6):1318-24. Exclude Code: E1. [pmid: 11099583].
136 Gustafson DH, et al. CHESS: 10 years of research and development in consumer health informatics for broad populations, including the underserved. International Journal of Medical Informatics. 2002;65(3):169-77. Exclude Code: E2. [pmid: 12414016].
137 Hahn EA, et al. The talking touchscreen: a new approach to outcomes assessment in low literacy. Psycho-Oncology. 2004;13(2):86-95. Exclude Code: E3. [pmid: 14872527].
138 Han HR, Belcher AE. Computer-mediated support group use among parents of children with cancer—an exploratory study. Computers in Nursing. 2001;19(1):27-33. Exclude Code: E1. [pmid: 11210451].
139 Hebert MA, Korabek B. Stakeholder readiness for telehomecare: implications for implementation. Telemedicine Journal & E-Health. 2004;10(1):85-92. Exclude Code: E3. [pmid: 15104920].
140 Hebert MA, Paquin MJ, Iversen S. Predicting success: stakeholder readiness for home telecare diabetic support. Journal of Telemedicine & Telecare. 2002;8(Suppl 3):S3:33-6. Exclude Code: E3.
141 Heiberg T, et al. Daily health status registration (patient diary) in patients with rheumatoid arthritis: a comparison between personal digital assistant and paper-pencil format. Arthritis & Rheumatism. 2007;57(3):454-60. Exclude Code: E3. [pmid: 17394232].
142 Heidgerken AD, et al. Telehealth intervention for adolescents with type 1 diabetes. Journal of Pediatrics. 2006;148(5):707-8. Exclude Code: E3. [pmid: 16737898].
143 Heisler M, et al. “I am not alone”: the feasibility and acceptability of interactive voice response-facilitated telephone peer support among older adults with heart failure. Congestive Heart Failure. 2007;13(3):149-57. Exclude Code: E3. [pmid: 17541307].
144 Hill W, Weinert C, Cudney S. Influence of a computer intervention on the psychological status of chronically ill rural women: preliminary results. Nursing Research. 2006;55(1):34-42. Exclude Code: E3. [pmid: 16439927].
145 Hill WG, Weinert C. An evaluation of an online intervention to provide social support and health education. CIN: Computers, Informatics, Nursing. 2004;22(5):282-8. Exclude Code: E1.
146 Hoffmann T, et al. Randomised trial of a computer-generated tailored written education package for patients following stroke. Age & Ageing. 2007;36(3):280-6. Exclude Code: E3. [pmid: 17360794].
147 Hoffmann T, Russell T, McKenna K. Producing computer-generated tailored written information for stroke patients and their carers: system development and preliminary evaluation. International Journal of Medical Informatics. 2004;73(1112):751-8. Exclude Code: E3. [pmid: 15491926].
148 Hofmann M, et al. Interactive computer-based cognitive training in patients with Alzheimer's disease. Journal of Psychiatric Research. 1996;30(6):493-501. Exclude Code: E3. [pmid: 9023793].
149 Holbrook A, et al. Influence of decision aids on patient preferences for anticoagulant therapy: a randomized trial. CMAJ Canadian Medical Association Journal. 2007;176(11):1583-7. Exclude Code: E3.
150 Hong O, et al. Efficacy of a computer-based hearing test and tailored hearing protection intervention. International Journal of Behavioral Medicine. 2006;13(4):304-14. Exclude Code: E3. [pmid: 17228988].
151 Hudson LR, et al. Remote physiological monitoring: clinical, financial, and behavioral outcomes in a heart failure population. Disease Management. 2005;8(6):372-81. Exclude Code: E3. [pmid: 16351555].
152 Hunkeler EM, et al. Efficacy of nurse telehealth care and peer support in augmenting treatment of depression in primary care. Archives of Family Medicine. 2000;9(8):700-8. Exclude Code: E3. [pmid: 10927707].
153 Huss K, et al. Computer game for inner-city children does not improve asthma outcomes. Journal of Pediatric Health Care. 2003;17(2):72-8. Exclude Code: E3. [pmid: 12665729].
154 Illyes M, Mengden T, Tisler A. The virtual hypertension clinic. Blood Pressure Monitoring. 2002;7(1):67-8. Exclude Code: E2. [pmid: 12040248].
155 Im EO, Chee W. Evaluation of the decision support computer program for cancer pain management. Oncology Nursing Forum Online. 2006;33(5):977-82. Exclude Code: E3.
156 James SD, Thomas RE. Problems in community healthcare information systems: a case study. Health Informatics Journal. 1999;5(3):146-53. Exclude Code: E2.
157 Jantz C, Anderson J, Gould SM. Using computer-based assessments to evaluate interactive multimedia nutrition education among low-income predominantly Hispanic participants. Journal of Nutrition Education and Behavior. 2002;34(5):252-60. Exclude Code: E3. [pmid: 12559060].
158 Jenkins RL, McSweeney M. Assessing elderly patients with congestive heart failure via in-home interactive telecommunication. Journal of Gerontological Nursing. 2001;27(1):21-7. Exclude Code: E3.
159 Jerant AF, Azari R, Nesbitt TS. Reducing the cost of frequent hospital admissions for congestive heart failure: a randomized trial of a home telecare intervention. Medical Care. 2001;39(11):1234-1245. Exclude Code: E3. [pmid: 11606877].
160 Jibaja-Weiss ML, et al. Entertainment education for informed breast cancer treatment decisions in low-literate women: development and initial evaluation of a patient decision aid. Journal of Cancer Education. 2006;21(3):133-9. Exclude Code: E3. [pmid: 17371175].
161 Johnson MJ, et al. The development and evaluation of alternative communication strategies to facilitate interactions with Somali refugees in primary care: a preliminary study. Informatics in Primary Care. 2006;14(3):183-9. Exclude Code: E3.
162 Johnston B, et al. Outcomes of the Kaiser Permanente Tele-Home Health Research Project. Archives of Family Medicine. 2000;9(1):40-5. Exclude Code: E3. [pmid: 10664641].
163 Kaminer Y, et al. An interactive voice response (IVR) system for adolescents with alcohol use disorders: a pilot study. American Journal on Addictions. 2006;15(Suppl 1):122-5. Exclude Code: E3. [pmid: 17182427].
164 Kaplan B, Farzanfar R, Friedman RH. Personal relationships with an intelligent interactive telephone health behavior advisor system: a multimethod study using surveys and ethnographic interviews. International Journal of Medical Informatics. 2003;71(1):33-41. Exclude Code: E1. [pmid: 12909156].
165 Karagiannis GE, et al. Health and lifestyle management via interactive TV in patients with severe chronic cardiovascular diseases. Journal of Telemedicine & Telecare. 2006;12(Suppl 1):17-9. Exclude Code: E3. [pmid: 16884567].
166 Karp WB, et al. Use of telemedicine for children with special health care needs. Pediatrics. 2000;105(4 part 1):843-7. Exclude Code: E3. [pmid: 10742330].
167 Katz N, et al. Interactive virtual environment training for safe street crossing of right hemisphere stroke patients with unilateral spatial neglect. Disability & Rehabilitation. 2005;27(20):1235-43. Exclude Code: E3. [pmid: 16298925].
168 Kaufman, D.R., et al., A cognitive framework for understanding barriers to the productive use of a diabetes home telemedicine system. AMIA, 2003. Annual Symposium Proceedings/AMIA Symposium.: p. 356–60. Exclude Code: E2
169 Kearney N, et al. Utilising handheld computers to monitor and support patients receiving chemotherapy: results of a UK-based feasibility study. Supportive Care in Cancer. 2006;14(7):742-52. Exclude Code: E3. [pmid: 16525792].
170 Keaton L, et al. An E-rehabilitation team helps caregivers deal with stroke. Internet Journal of Allied Health Sciences & Practice. 2004;2(4):17p. Exclude Code: E1.
171 Keener, R.E., Tracking HIV treatment: technology and drugs make AIDS a manageable disease. Health Management Technology, 2000. 21(10): p. 48, 50–1. Exclude Code: E3
172 Kerr C, et al. Internet interventions for long-term conditions: patient and caregiver quality criteria. Journal of Medical Internet Research. 2006;8(3):e13. Exclude Code: E. [pmid: 16954123].
173 Keulers BJ, et al. Can face-to-face patient education be replaced by computer-based patient education? A randomised trial. Patient Education and Counseling. 2007;67(12):176-82. Exclude Code: E3. [pmid: 17448621].
174 Kim HS, Yoo YS, Shim HS. Effects of an Internet-based intervention on plasma glucose levels in patients with type 2 diabetes. Journal of Nursing Care Quality. 2005;20(4):335-40. Exclude Code: E3. [pmid: 16177585].
175 Kinsella A. Managing technology. Telehealthcare under PPS: tools to make it work. Home Healthcare Nurse. 2001;19(9):579-81. Exclude Code: E2. [pmid: 11982200].
176 Kinzie MB, Schorling JB, Siegel M. Prenatal alcohol education for low-income women with interactive multimedia. Patient Education and Counseling. 1993;21(1/2):51-60. Exclude Code: E3. [pmid: 8337205].
177 Kleinpell RM, Avitall B. Integrating telehealth as a strategy for patient management after discharge for cardiac surgery: results of a pilot study. Journal of Cardiovascular Nursing. 2007;22(1):38-42. Exclude Code: E3. [pmid: 17224696].
178 Kreisel K. Evaluation of a computer-based nutrition education tool. Public Health Nutrition. 2004;7(2):271-7. Exclude Code: E1. [pmid: 15003134].
179 Krishna S, et al. Internet-enabled interactive multimedia asthma education program: a randomized trial. Pediatrics. 2003;111(3):503-10. Exclude Code: E3. [pmid: 12612228].
180 Krishna S, et al. Internet-enabled interactive multimedia asthma education program: a randomized trial. Pediatrics. 2003;111(3):503-10. Exclude Code: E3. [pmid: 12612228].
181 Kukafka R, et al. Web-based tailoring and its effect on self-efficacy: results from the MI-HEART randomized controlled trial. Proceedings / AMIA. 2002;Annual Symposium:410-4. Exclude Code: E1.
182 Kully D. Telehealth in speech pathology: applications to the treatment of stuttering. Journal of Telemedicine & Telecare. 2000;6(Suppl 2):S39-41. Exclude Code: E3. [pmid: 10975096].
183 Laron Z, et al. Four years experience with the microcomputer system “Diacon” in the treatment and education of diabetes. Hormone & Metabolic Research - Supplement. 1990;24:129-40. Exclude Code: E3.
184 Latessa RA, et al. Changing practices in the use of pneumococcal vaccine. Family Medicine. 2000;32(3):196-200. Exclude Code: E3. [pmid: 10726221].
185 Lawton, D.F., Older Adults Eager To Explore Cyberspace. 2001. Exclude Code: E3
186 Leahy A, et al. Computerised biofeedback games: a new method for teaching stress management and its use in irritable bowel syndrome. Journal of the Royal College of Physicians of London. 1998;32(6):552-6. Exclude Code: E3. [pmid: 9881312].
187 Lee JH, et al. A telemedicine system as a care modality for dementia patients in Korea. Alzheimer Disease & Associated Disorders. 2000;14(2):94-101. Exclude Code: E3. [pmid: 10850748].
188 Lehmann ED. Spontaneous comments from users of the AIDA interactive educational diabetes simulator. Diabetes Educator. 26(4):633-8. Exclude Code: E3.
189 Lehmann ED. Preliminary experience with the Internet release of AIDA—an interactive educational diabetes simulator. Computer Methods & Programs in Biomedicine. 1998;56(2):109-32. Exclude Code: E3. [pmid: 9700427].
190 Lehmann ED. Experience with the Internet release of AIDA v4.0—http://www.diabetic.org.uk.aida.htm—an interactive educational diabetes simulator. Diabetes Technology & Therapeutics. 1999;1(1):41-54. Exclude Code: E3. [pmid: 11475304].
191 Lehmann ED. The freeware AIDA interactive educational diabetes simulator—http://www.2aida.org—(1). A download survey for AIDA v4.0. Medical Science Monitor. 2001;7(3):504-15. Exclude Code: E3. [pmid: 11386033].
192 Lehmann ED. Why are people downloading the freeware AIDA diabetes computing software program: a pilot study. Diabetes Technology & Therapeutics. 2002;4(6):793-808. Exclude Code: E3. [pmid: 12685803].
193 Lehmann ED. Who is downloading the freeware AIDA v43 interactive educational diabetes simulator? An audit of 2437 downloads. Diabetes Technology & Therapeutics. 2002;4(4):467-77. Exclude Code: E3. [pmid: 12396741].
194 Lehmann ED. Who is downloading the free AIDA v4.3a interactive educational diabetes computer software? A 1-year survey of 3864 downloads. Diabetes Technology & Therapeutics. 2003;5(5):879-90. Exclude Code: E3. [pmid: 14633359].
195 Lehmann ED. Why people download the freeware AIDA v4.3a diabetes software program: a proof-of-concept semi-automated analysis. Diabetes Technology & Therapeutics. 2003;5(3):477-90. Exclude Code: E3. [pmid: 12828835].
196 Lehmann ED. Research use of the AIDA www.2aida.org diabetes software simulation program: a review-part 1. decision support testing and neural network training. Diabetes Technology & Therapeutics. 2003;5(3):425-38. Exclude Code: E2. [pmid: 12828827].
197 Lehmann ED. Usage of the www.2aida.org AIDA diabetes software Website: a pilot study. Diabetes Technology & Therapeutics. 2003;5(1):75-89. Exclude Code: E3. [pmid: 12725710].
198 Lehmann ED. British Diabetic Association review of the AIDA v4 diabetes software simulator program. Diabetes Technology & Therapeutics. 2004;6(1):87-96. Exclude Code: E3. [pmid: 15000776].
199 Lehmann, E.D. and T. Deutsch, An interactive, educational model for insulin dosage and dietary adjustment in type I diabetes mellitus. Proceedings - the Annual Symposium on Computer Applications in Medical Care, 1992: p. 205–9. Exclude Code E3
200 Levetan CS, et al. Impact of computer-generated personalized goals on HbA(1c). Diabetes Care. 2002;25(1):2-8. Exclude Code: E3. [pmid: 11772893].
201 Lewis, D., J. Cooper, and S. Gunawardena, Caring Connection: Internet resources for family caregivers of children with cancer. AMIA, 2006. Annual Symposium Proceedings/AMIA Symposium.: p. 1007. Exclude Code: E1
202 Lillis K. Electronically enhanced therapy: behavioral health plan rolls out online, interactive “coaching” series for members. Health Management Technology. 2004;25(8):42. Exclude Code: E2.
203 Lin Z, Effken J, Li Y. Designing and evaluating a Web-based, tailored breast cancer education program. CIN: Computers, Informatics, Nursing. 2006;24(5):300. Exclude Code: E.
204 Linke S, et al. Internet-based interactive health intervention for the promotion of sensible drinking: patterns of use and potential impact on members of the general public. Journal of Medical Internet Research. 2007;9(2):e10. Exclude Code: E1. [pmid: 17513281].
205 Linne AB, Liedholm H. Effects of an interactive CD-program on 6 months readmission rate in patients with heart failure - a randomised, controlled trial [NCT00311194]. BMC Cardiovascular Disorders. 2006;6:30. Exclude Code: E3. [pmid: 16796760].
206 Lo R, et al. The development and evaluation of a computer-aided diabetes education program. Australian Journal of Advanced Nursing. 1996;13(4):19-27. Exclude Code: E3. [pmid: 8900703].
207 Long JD, et al. Pilot using world wide Web to prevent diabetes in adolescents. Clinical Nursing Research. 2006;15(1):67-79. Exclude Code: E. [pmid: 16410623].
208 Lopez AM, et al. Increasing access to care via tele-health: the Arizona experience. Journal of Ambulatory Care Management. 2005;28(1):16-23. Exclude Code: E3. [pmid: 15682957].
209 Lovell K, et al. Telephone administered cognitive behaviour therapy for treatment of obsessive compulsive disorder: randomised controlled non-inferiority trial. BMJ. 2006;333(7574):883-6. Exclude Code: E3. [pmid: 16935946].
210 Lowe P, Hearnshaw H, Griffiths F. Attitudes of young people with diabetes to an Internet-based virtual clinic. Journal of Telemedicine & Telecare. 2005;11(Suppl 1):59-60. Exclude Code: E3. [pmid: 16035996].
211 Maaske L. A study of interactivity in educational patient hypermedia. Journal of Biocommunication. 1999;26(3):2-11. Exclude Code: E3. [pmid: 10659444].
212 Mackenzie SLC, et al. Patient and staff perspectives on the use of a computer counseling tool for HIV and sexually transmitted infection risk reduction. Journal of Adolescent Health. 2007;40(6):572e9-16. Exclude Code: E3.
213 Mahoney DF, et al. Effects of a multimedia project on users' knowledge about normal forgetting and serious memory loss. Journal of the American Medical Informatics Association. 2002;9(4):383-94. Exclude Code: E3. [pmid: 12087119].
214 Malasanos TH, et al. School nurse, family and provider connectivity in the FITE diabetes project. Journal of Telemedicine & Telecare. 2005;11(Suppl 1):76-8. Exclude Code: E3. [pmid: 16036003].
215 Marco CA, Larkin GL. Public education regarding resuscitation: effects of a multimedia intervention. Annals of Emergency Medicine. 2003;42(2):256-60. Exclude Code: E3. [pmid: 12883514].
216 Markman M, et al. Profile of ovarian cancer patients seeking information from a web-based decision support program. Journal of Women's Health. 2006;15(3):312-8. Exclude Code: E3.
217 Matheson D, Achterberg C. Ecologic study of children's use of a computer nutrition education program. Journal of Nutrition Education. 2001;33(1):2-9. Exclude Code: E1. [pmid: 12031199].
218 Matthew AG, et al. Serial personal digital assistant data capture of health-related quality of life: a randomized controlled trial in a prostate cancer clinic. Health & Quality of Life Outcomes. 2007;5:38. Exclude Code: E3. [pmid: 17617906].
219 McGrew KB, Quinn CA. Examining the effectiveness of telephone assessment and care planning for homecare services. Generations. 1997;21(1):66-67. Exclude Code: E3.
220 Meneghini LF, et al. An electronic case manager for diabetes control. Diabetes Care. 1998;21(4):591-6. Exclude Code: E3. [pmid: 9571348].
221 Mengden T, et al. Telemonitoring of blood pressure self measurement in the OLMETEL study... Proceedings from the “European Society of Hypertension Working Group on Blood Pressure Monitoring Scientific Workshop: What's New in Blood Pressure Measurement?”; held June 2004 in Paris, France. Blood Pressure Monitoring. 2004;9(6):321-5. Exclude Code: E3. [pmid: 15564988].
222 Mermelstein R, Turner L. Web-based support as an adjunct to group-based smoking cessation for adolescents. Nicotine & Tobacco Research. 2006;8(Suppl 1):S69-76. Exclude Code: E3. [pmid: 17491173].
223 Meyerhoff C, Bischof F, Pfeiffer EF. Long-term experiences with a computerized diabetes management and glucose monitoring system in insulin-dependent diabetic patients. Diabetes Research & Clinical Practice. 1994;24(1):1-7. Exclude Code: E3. [pmid: 7924881].
224 Miloud, G.L., Response to: Heartcare: an Internet-based information and support system for patient home recovery after coronary artery bypass graft (CABG) surgery by P. Flatley Brennan, S.M. Moore, G. Bjornsdottir, J. Jones, C. Visovsky and M. Rogers (2001) Journal Of Advanced Nursing 35, 699–708. Journal of Advanced Nursing, 2002. 38(4): p. 425; author reply 425–6. Exclude Code: E
225 Molenaar S, et al. Exploring the black box of a decision aid: what information do patients select from an interactive Cd-Rom on treatment options in breast cancer?. Patient Education & Counseling. 2007;65(1):122-30. Exclude Code: E3. [pmid: 16945498].
226 Molenaar S, et al. Decision support for patients with early-stage breast cancer: effects of an interactive breast cancer CDROM on treatment decision, satisfaction, and quality of life. Journal of Clinical Oncology. 2001;19(6):1676-87. Exclude Code: E3. [pmid: 11250997].
227 Morlion B, et al. Internet-based home monitoring of pulmonary function after lung transplantation. American Journal of Respiratory & Critical Care Medicine. 2002;165(5):694-7. Exclude Code: E3. [pmid: 11874816].
228 Mullan B, et al. Home monitoring for lung transplant candidates. Progress in Transplantation. 2003;13(3):176-82. Exclude Code: E3. [pmid: 14558631].
229 Murtagh MJ, et al. Qualitative methods in a randomised controlled trial: the role of an integrated qualitative process evaluation in providing evidence to discontinue the intervention in one arm of a trial of a decision support tool. Quality & Safety in Health Care. 2007;16(3):224-9. Exclude Code: E3. [pmid: 17545351].
230 Nakajima K, et al. Low-cost, email-based system for self blood pressure monitoring at home. Journal of Telemedicine & Telecare. 2006;12(4):203-7. Exclude Code: E3. [pmid: 16774703].
231 Nakamura K, Takano T, Akao C. Effectiveness of videophones in home healthcare for the elderly. Medical Care. 1999;37(2):117-125. Exclude Code: E3. [pmid: 10024116].
232 Neafsey PJ, et al. An interactive technology approach to educate older adults about drug interactions arising from over-the-counter self-medication practices. Public Health Nursing. 2002;19(4):255-62. Exclude Code: E3. [pmid: 12071899].
233 Nebel IT, et al. Evaluation of a computer based interactive diabetes education program designed to train the estimation of the energy or carbohydrate contents of foods. Patient Education & Counseling. 2002;46(1):55-9. Exclude Code: E3. [pmid: 11804770].
234 Nebel IT, et al. Comparative analysis of conventional and an adaptive computer-based hypoglycaemia education programs. Patient Education & Counseling. 2004;53(3):315-8. Exclude Code: E3. [pmid: 15186869].
235 Neville R, et al. Mobile phone text messaging can help young people manage asthma. BMJ. 2002;325(7364):600. Exclude Code: E3. [pmid: 12228151].
236 Neville R, et al. E-mail consultations in general practice. British Journal of General Practice. 2004;54(504):546. Exclude Code: E. [pmid: 15256037].
237 Neville RG, et al. Email consultations in general practice. Informatics in Primary Care. 2004;12(4):207-14. Exclude Code: E1.
238 Nijeweme-d'Hollosy WO, et al. Tele-treatment of patients with amyotrophic lateral sclerosis (ALS). Journal of Telemedicine & Telecare. 2006;12(Suppl 1):31-4. Exclude Code: E3. [pmid: 16884573].
239 Oberleitner R, Laxminarayan S. Information technology and behavioral medicine: impact on autism treatment & research. Studies in Health Technology & Informatics. 2004;103:215-22. Exclude Code: E2. [pmid: 15747924].
240 Ogawa H, et al. A web-based care-requiring client and Home Helper mutual support system. Biomedical Sciences Instrumentation. 2005;41:159-62. Exclude Code: E. [pmid: 15850098].
241 O'Grady LA. Consumer e-health education in HIV/AIDS: a pilot study of a web-based video workshop. BMC Medical Informatics & Decision Making. 2006;6:10. Exclude Code: E1. [pmid: 16504148].
242 Osman LM, et al. Reducing hospital admission through computer supported education for asthma patients. BMJ. 1994;308(6928):568-71. Exclude Code: E3. [pmid: 8093148].
243 Owens BH, Robbins KC. CHESS: comprehensive health enhancement support system for women with breast cancer. Plastic Surgical Nursing. 16(3):172-5. Exclude Code: E2.
244 Page SJ, Levine P. Modified constraint-induced therapy extension: using remote technologies to improve function. Archives of Physical Medicine & Rehabilitation. 2007;88(7):922-7. Exclude Code: E3. [pmid: 17601475].
245 Palermo TM, Valenzuela D, Stork PP. A randomized trial of electronic versus paper pain diaries in children: impact on compliance, accuracy, and acceptability. Pain. 2004;107(3):213-9. Exclude Code: E3. [pmid: 14736583].
246 Papadaki A, Scott JA. The Mediterranean Eating in Scotland Experience project: evaluation of an Internet-based intervention promoting the Mediterranean diet. British Journal of Nutrition. 2005;94(2):290-8. Exclude Code: E. [pmid: 16115365].
247 Papakonstantinou E, et al. Assessment of perceptions of nutrition knowledge and disease using a group interactive system: the PERCEPTION ANALYZER. Journal of the American Dietetic Association. 2002;102(11):1663-8. Exclude Code: E1. [pmid: 12449292].
248 Peters AL, Davidson MB. Application of a diabetes managed care program. The feasibility of using nurses and a computer system to provide effective care. Diabetes Care. 1998;21(7):1037-43. Exclude Code: E3. [pmid: 9653591].
249 Petersen M. What are blood counts? A computer-assisted program for pediatric patients. Pediatric Nursing. 1996;22(1):21-5. quiz 26–7. Exclude Code: E3. [pmid: 8700621].
250 Phelps-Fredette S. Cardiology patient page. Learn, take action, and live: a guide to using online tools to prevent and manage heart disease and stroke. Circulation. 2005;112(20):e318-9. Exclude Code: E2. [pmid: 16286593].
251 Pierce LL, Steiner V, Govoni AL. In-home online support for caregivers of survivors of stroke: a feasibility study. CIN: Computers, Informatics, Nursing. 2002;20(4):157-64. Exclude Code: E1.
252 Pierce LL, et al. Internet-based support for rural caregivers of persons with stroke shows promise. Rehabilitation Nursing. 29(3):95-9. Exclude Code: E1.
253 Plougmann S, Hejlesen OK, Cavan DA. DiasNet—a diabetes advisory system for communication and education via the internet. International Journal of Medical Informatics. 2001;64(23):319-30. Exclude Code: E2. [pmid: 11734394].
254 Port K, Palm K, Viigimaa M. Daily usage and efficiency of remote home monitoring in hypertensive patients over a one-year period. Journal of Telemedicine & Telecare. 2005;11(Suppl 1):34-6. Exclude Code: E3. [pmid: 16035987].
255 Porter SC, et al. The asthma kiosk: a patient-centered technology for collaborative decision support in the emergency department. Journal of the American Medical Informatics Association. 2004;11(6):458-67. Exclude Code: E. [pmid: 15298999].
256 Porter SC, et al. Impact of patient-centered decision support on quality of asthma care in the emergency department. Pediatrics. 2006;117(1):e33-42. Exclude Code: E3. [pmid: 16396846].
257 Porter SC, et al. Parents as direct contributors to the medical record: validation of their electronic input. Annals of Emergency Medicine. 2000;35(4):346-52. Exclude Code: E1. [pmid: 10736120].
258 Pyper C, et al. Access to electronic health records in primary care-a survey of patients' views. Medical Science Monitor. 2004;10(11):SR17-22. Exclude Code: E1. [pmid: 15507869].
259 Redsell SA, et al. Multimedia versus written information for nocturnal enuresis education: a cluster randomized controlled trial. Child: Care, Health & Development. 2003;29(2):121-9. Exclude Code: E3.
260 Reis J, McGinty B, Jones S. An e-learning caregiving program for prostate cancer patients and family members. Journal of Medical Systems. 2003;27(1):1-12. Exclude Code: E3. [pmid: 12617194].
261 Rice VH, et al. Exemplary program development: hypermedia interactive smoking cessation intervention program for pregnant women... including commentary by Budin WC. Journal of Perinatal Education. 1997;6(3):47-61. Exclude Code: E3.
262 Riley ED, et al. Use of audio computer-assisted self-interviews to assess tuberculosis-related risk behaviors. American Journal of Respiratory & Critical Care Medicine. 2001;164(1):82-5. Exclude Code: E3. [pmid: 11435243].
263 Riva A, Bellazzi R, Stefanelli M. A Web-based system for the intelligent management of diabetic patients. MD Computing. 1997;14(5):360-4. Exclude Code: E2. [pmid: 9308344].
264 Robbins KC. CHESS: the Comprehensive Health Enhancement Support System. A computer based program for patients and families. Connecticut Nursing News. 1999;72(1):14. Exclude Code: E2. [pmid: 10614238].
265 Rogers A, Mead N. More than technology and access: primary care patients' views on the use and non-use of health information in the Internet age. Health and Social Care in the Community. 2004;12(2):102-10. Exclude Code: E3. [pmid: 19777718].
266 Rosen J, et al. Educating the families of nursing home residents: a pilot study using a computer-based system. Journal of the American Medical Directors Association. 2003;4(3):128-34. Exclude Code: E1. [pmid: 12854985].
267 Roumie CL, et al. A three-part intervention to change the use of hormone replacement therapy in response to new evidence. Annals of Internal Medicine. 2004;141(2):118-25. Exclude Code: E1. [pmid: 15262667].
268 Rutscher A, Salzsieder E, Fischer U. KADIS: model-aided education in type I diabetes. Karlsburg Diabetes Management System. Computer Methods & Programs in Biomedicine. 1994;41(34):205-15. Exclude Code: E. [pmid: 8187466].
269 Sabati N, et al. Facilitators and barriers to adherence with home monitoring using electronic spirometry. AACN Clinical Issues. 2001;12(2):178-85. Exclude Code: E3. [pmid: 11759546].
270 Sanchez-Franco MJ. Exploring the influence of gender on the web usage via partial least squares. Behaviour & Information Technology. 2006;25(1):19-36. Exclude Code: E3.
271 Scherr D, et al. Mobile phone-based surveillance of cardiac patients at home. Journal of Telemedicine & Telecare. 2006;12(5):255-61. Exclude Code: E3. [pmid: 16848939].
272 Schinke SP, et al. Feasibility of interactive videodisc technology to teach minority youth about preventing HIV infection. Public Health Reports. 1992;107(3):323-30. Exclude Code: E3. [pmid: 1375760].
273 Schrot RJ, et al. A computerized model for home glucose monitoring proficiency testing: efficacy of an innovative testing program. Diabetes Educator. 1999;25(1):48-55. Exclude Code: E3. [pmid: 10232180].
274 Sciamanna CN, et al. Effects of a Website designed to improve the management of migraines. Headache. 2006;46(1):92-100. Exclude Code: E3. [pmid: 16412156].
275 Sciamanna CN, et al. Visit satisfaction and tailored health behavior communications in primary care. American Journal of Preventive Medicine. 2004;26(5):426-30. Exclude Code: E3. [pmid: 15165659].
276 Sequist TD, et al. A randomized trial of electronic clinical reminders to improve quality of care for diabetes and coronary artery disease. Journal of the American Medical Informatics Association. 2005;12(4):431-7. Exclude Code: E3. [pmid: 15802479].
277 Sevick MA, et al. A preliminary study of PDA-based dietary self-monitoring in hemodialysis patients. Journal of Renal Nutrition. 2005;15(3):304-11. Exclude Code: E3. [pmid: 16007560].
278 Shah NB, et al. Prevention of hospitalizations for heart failure with an interactive home monitoring program. American Heart Journal. 1998;135(3):373-8. Exclude Code: E3. [pmid: 9506321].
279 Shames RS, et al. Effectiveness of a multicomponent self-management program in at-risk, school-aged children with asthma. Annals of Allergy, Asthma, & Immunology. 2004;92(6):611-8. Exclude Code: E3.
280 Shaw B, et al. How Underserved Breast Cancer Patients Use and Benefit From eHealth Programs: Implications for Closing the Digital Divide. American Behavioral Scientist. 2006;49(6):823-834. Exclude Code: E2.
281 Sims, T.L., et al., Multimedia quality of life assessment: advances with FLAIR. AMIA, 2005. Annual Symposium Proceedings/AMIA Symposium.: p. 694–8. Exclude Code: E3
282 Sixsmith AJ. An evaluation of an intelligent home monitoring system. Journal of Telemedicine & Telecare. 2000;6(2):63-72. Exclude Code: E3. [pmid: 10824373].
283 Slootmaker SM, et al. Promoting physical activity using an activity monitor and a tailored web-based advice: design of a randomized controlled trial [ISRCTN93896459]. BMC Public Health. 2005;5:134. Exclude Code: E2. [pmid: 16356182].
284 Soghikian K, et al. Home blood pressure monitoring. Effect on use of medical services and medical care costs. Medical Care. 1992;30(9):855-65. Exclude Code: E3. [pmid: 1518317].
285 Starren J, et al. Columbia University's Informatics for Diabetes Education and Telemedicine (IDEATel) project: technical implementation. Journal of the American Medical Informatics Association. 2002;9(1):25-36. Exclude Code: E3. [pmid: 11751801].
286 Steel S, et al. A feasibility study of remote monitoring of asthmatic patients. Journal of Telemedicine & Telecare. 2002;8(5):290-6. Exclude Code: E3. [pmid: 12396858].
287 Steier J, et al. Optical feedback training of inhalation with Autohaler and Turbuhaler in COPD patients. Lung. 2003;181(4):183-92. Exclude Code: E3. [pmid: 14692558].
288 Stillman JK, et al. Telepaediatrics and diabetic retinopathy screening of young people with diabetes in Queensland. Journal of Telemedicine & Telecare. 2004;10(Suppl 1):92-4. Exclude Code: E3. [pmid: 15603624].
289 Stricklin MLV, Jones S, Niles SA. HOME TALK/healthy talk: improving patients' health status with telephone technology. Home Healthcare Nurse. 2000;18(1):53-62. Exclude Code: E3. [pmid: 11011651].
290 Stromberg A, et al. Interactive education on CD-ROM-a new tool in the education of heart failure patients. Patient Education & Counseling. 2002;46(1):75-81. Exclude Code: E3. [pmid: 11804773].
291 Sun P, et al. Internet accessibility and usage among urban adolescents in Southern California: implications for web-based health research. Cyberpsychology & Behavior. 2005;8(5):441-53. Exclude Code: E. [pmid: 16232037].
292 Suzuki LK, Beale IL. Personal Web home pages of adolescents with cancer: self-presentation, information dissemination, and interpersonal connection. Journal of Pediatric Oncology Nursing. 2006;23(3):152-61. Exclude Code: E3. [pmid: 16624891].
293 Sweeney NM, Glaser D, Tedeschi C. The eating and physical activity habits of inner-city adolescents. Journal of Pediatric Health Care. 2007;21(1):13-21. Exclude Code: E3. [pmid: 17198895].
294 Tam S, et al. Evaluating the efficacy of tele-cognitive rehabilitation for functional performance in three case studies. Occupational Therapy International. 2003;10(1):20-38. Exclude Code: E3. [pmid: 12830317].
295 Tang, P.C., et al., PAMFOnline: integrating EHealth with an electronic medical record system. AMIA, 2003. Annual Symposium Proceedings/AMIA Symposium.: p. 644–8. Exclude Code: E1
296 Tessaro I, et al. Effectiveness of a nutrition intervention with rural low-income women. American Journal of Health Behavior. 2007;31(1):35-43. Exclude Code: E3. [pmid: 17181460].
297 Thomson RG, et al. A patient decision aid to support shared decision-making on anti-thrombotic treatment of patients with atrial fibrillation: randomised controlled trial. Quality & Safety in Health Care. 2007;16(3):216-23. Exclude Code: E3. [pmid: 17545350].
298 Tomuro K. Oral home telecare tutorials for the community-dwelling elderly. Journal of Medical & Dental Sciences. 2004;51(3):165-71. Exclude Code: E3. [pmid: 15597822].
299 Tudiver F, et al. Primary care providers' perceptions of home diabetes telemedicine care in the IDEATel project. Journal of Rural Health. 2007;23(1):55-61. Exclude Code: E1.
300 Van Biervliet A, Gest TR. A multimedia guide to spinal cord injury: empowerment through self instruction. Medinfo. 1995;8(Pt 2):1701. Exclude Code: E3. [pmid: 8591558].
301 Van Diest SL, et al. Sex therapy through the internet for men with sexual dysfunctions: a pilot study. Journal of Sex & Marital Therapy. 2007;33(2):115-33. Exclude Code: E3. [pmid: 17365513].
302 van Eijken M, et al. Interventions to improve medication compliance in older patients living in the community: a systematic review of the literature. Drugs & Aging. 2003;20(3):229-40. Exclude Code: E. [pmid: 12578402].
303 van Lankveld WGJM, Derks AM, van den Hoogen FHJ. Disease related use of the internet in chronically ill adults: current and expected use. Annals of the Rheumatic Diseases. 2006;65(1):121-3. Exclude Code: E2. [pmid: 15919680].
304 Verheijden M, et al. Web-based targeted nutrition counselling and social support for patients at increased cardiovascular risk in general practice: randomized controlled trial. Journal of Medical Internet Research. 2004;6(4):e44. Exclude Code: E. [pmid: 15631968].
305 Verheijden MW, et al. Rates and determinants of repeated participation in a web-based behavior change program for healthy body weight and healthy lifestyle. Journal of Medical Internet Research. 2007;9(1):e1. Exclude Code: E1. [pmid: 17478410].
306 Walker H. Computer-based education for patients with psychosis. Nursing Standard. 2006;20(30):49-56. Exclude Code: E3. [pmid: 16623293].
307 Waller A, et al. Participatory design of a text message scheduling system to support young people with diabetes. Health Informatics Journal. 2006;12(4):304-18. Exclude Code: E3. [pmid: 17093001].
308 Wangberg SC, Arsand E, Andersson N. Diabetes education via mobile text messaging. Journal of Telemedicine & Telecare. 2006;12(Suppl 1):55-6. Exclude Code: E. [pmid: 16884582].
309 Weber B, et al. Computerized self-assessment in psychiatric in-patients: acceptability, feasibility and influence of computer attitude. Acta Psychiatrica Scandinavica. 1998;98(2):140-5. Exclude Code: E1. [pmid: 9718241].
310 Weinert C, Cudney S, Winters C. Social support in cyberspace: the next generation. CIN: Computers, Informatics, Nursing. 2005;23(1):7-15. Exclude Code: E.
311 Welch J, Dowell S, Johnson CS. Feasibility of using a personal digital assistant to self-monitor diet and fluid intake: a pilot study. Nephrology Nursing Journal: Journal of the American Nephrology Nurses' Association. 2007;34(1):43-8. quiz 49. Exclude Code: E. [pmid: 17345691].
312 Wells M, et al. Online mental health treatment: concerns and considerations. Cyberpsychology & Behavior. 2007;10(3):453-9. Exclude Code: E1. [pmid: 17594270].
313 Westlake C, et al. Evaluation of a Web-based education and counseling pilot program for older heart failure patients. Progress in Cardiovascular Nursing. 2007;22(1):20-6. Exclude Code: E. [pmid: 17342002].
314 White C, Sheedy V, Lawrence N. Patterns of computer usage among medical practitioners in rural and remote Queensland. Australian Journal of Rural Health. 2002;10(3):137-46. Exclude Code: E1. [pmid: 12081506].
315 White MJ, et al. Implementing a computer-assisted telephone interview (CATI) system to increase colorectal cancer screening: a process evaluation. Patient Education & Counseling. 2006;61(3):419-28. Exclude Code: E1. [pmid: 15993558].
316 Whitlock WL, et al. Telemedicine improved diabetic management. Military Medicine. 2000;165(8):579-84. Exclude Code: E3. [pmid: 10957848].
317 Whittaker SL, et al. Success factors in the long-term sustainability of a telediabetes programme. Journal of Telemedicine & Telecare. 2004;10(2):84-8. Exclude Code: E3. [pmid: 15068643].
318 Whitten P, Collins B, Mair F. Nurse and patient reactions to a developmental home telecare system. Journal of Telemedicine & Telecare. 1998;4(3):152-60. Exclude Code: E3. [pmid: 10321043].
319 Whitten P, Doolittle G, Mackert M. Telehospice in Michigan: use and patient acceptance. American Journal of Hospice & Palliative Care. 2004;21(3):191-5. Exclude Code: E3. [pmid: 15188918].
320 Whitten P, et al. Telehospice carries end-of-life care over the lines. Nursing Management. 2003;34(11):36-9. Exclude Code: E3. [pmid: 14671449].
321 Whitten P, Kuwahara E. A multi-phase telepsychiatry programme in Michigan: organizational factors affecting utilization and user perceptions. Journal of Telemedicine & Telecare. 2004;10(5):254-61. Exclude Code: E3. [pmid: 15494082].
322 Whitten P, Love B. Patient and provider satisfaction with the use of telemedicine: overview and rationale for cautious enthusiasm. Journal of Postgraduate Medicine. 2005;51(4):294-300. Exclude Code: E2. [pmid: 16388172].
323 Whitten P, Mair F, Collins B. Home telenursing in Kansas: patients' perceptions of uses and benefits. Journal of Telemedicine & Telecare. 1997;3(Suppl 1):67-9. Exclude Code: E3. [pmid: 9218390].
324 Whitten P, Mickus M. Home telecare for COPD/CHF patients: outcomes and perceptions. Journal of Telemedicine & Telecare. 2007;13(2):69-73. Exclude Code: E3. [pmid: 17359569].
325 Whitten PS, Mair F. Telemedicine and patient satisfaction: current status and future directions. Telemedicine Journal & E-Health. 2000;6(4):417-23. Exclude Code: E2. [pmid: 11242550].
326 Wiecha, J.M. and W.G. Adams, BostonBreathes: improving pediatric asthma care with a home-based interactive website for patient education, monitoring, and clinical teamwork. AMIA, 2006. Annual Symposium Proceedings/AMIA Symposium.: p. 1144. Exclude Code: E2
327 Wilkie DJ, et al. Usability of a computerized PAINReportIt in the general public with pain and people with cancer pain. Journal of Pain and Symptom Management. 2003;25(3):213-24. Exclude Code: E3. [pmid: 12614956].
328 Williams C, et al. Efficacy of a drug prevention CD-ROM intervention for adolescents. Substance Use & Misuse. 2005;40(6):869-78. Exclude Code: E1. [pmid: 15974146].
329 Williams P, Nicholas D, Huntington P. Non use of health information kiosks examined in an information needs context. Health Information & Libraries Journal. 2003;20(2):95-103. Exclude Code: E1. [pmid: 12786908].
330 Williams T, et al. Patient satisfaction with store-and-forward teledermatology. Journal of Telemedicine & Telecare. 2001;7(Suppl 1):45-6. Exclude Code: E3. [pmid: 11576488].
331 Williams TL, et al. Patient satisfaction with teledermatology is related to perceived quality of life. British Journal of Dermatology. 2001;145(6):911-7. Exclude Code: E3. [pmid: 11899144].
332 Wilson A, et al. Investigating patients' and general practitioners' views of computerised decision support software for the assessment and management of cardiovascular risk. Informatics in Primary Care. 2007;15(1):33-44. Exclude Code: E1.
333 Wilson AE, Home PD. A dataset to allow exchange of information for monitoring continuing diabetes care. The Diabetes Audit Working Group. Diabetic Medicine. 1993;10(4):378-90. Exclude Code: E2. [pmid: 8508625].
334 Wilson PN, Foreman N, Stanton D. Virtual reality, disability and rehabilitation. Disability & Rehabilitation. 1997;19(6):213-20. Exclude Code: E2. [pmid: 9195138].
335 Winkelman WJ, Leonard KJ, Rossos PG. Patient-perceived usefulness of online electronic medical records: employing grounded theory in the development of information and communication technologies for use by patients living with chronic illness. Journal of the American Medical Informatics Association. 2005;12(3):306-14. Exclude Code: E3. [pmid: 15684128].
336 Wise M, et al. Internet telehealth for pediatric asthma case management: integrating computerized and case manager features for tailoring a Web-based asthma education program. Health Promotion Practice. 2007;8(3):282-91. Exclude Code: E. [pmid: 16928987].
337 Wolf JM, et al. Access and use of the internet in a hand surgery population. Hand Surgery. 2004;9(1):29-33. Exclude Code: E1. [pmid: 15368622].
338 Wolf SL, et al. Reducing frailty and falls in older persons: an investigation of Tai Chi and computerized balance training. Atlanta FICSIT Group. Frailty and Injuries: Cooperative Studies of Intervention Techniques. Journal of the American Geriatrics Society. 1996;44(5):489-97. Exclude Code: E3. [pmid: 8617895].
339 Woodall WG, et al. Effect of emailed messages on return use of a nutrition education website and subsequent changes in dietary behavior. Journal of Medical Internet Research. 2007;9(3):e27. Exclude Code: E3. [pmid: 17942389].
340 Woods KF, et al. Sickle cell disease telemedicine network for rural outreach. Journal of Telemedicine & Telecare. 2000;6(5):285-90. Exclude Code: E3. [pmid: 11070590].
341 Woods KF, et al. Sickle cell telemedicine and standard clinical encounters: a comparison of patient satisfaction. Telemedicine Journal. 1999;5(4):349-56. Exclude Code: E3. [pmid: 10908450].
342 Wright P, et al. Text entry on handheld computers by older users. Ergonomics. 2000;43(6):702-16. Exclude Code: E3. [pmid: 10902881].
343 Wright P, Belt S, John C. Helping people assess the health risks from lifestyle choices: comparing a computer decision aid with customized printed alternative. Communication & Medicine. 2004;1(2):183-92. Exclude Code: E1. [pmid: 16808700].
344 Wright P, et al. Enhancing an appointment diary on a pocket computer for use by people after brain injury. International Journal of Rehabilitation Research. 2001;24(4):299-308. Exclude Code: E. [pmid: 11775034].
345 Wu AW, et al. A randomized trial of the impact of a programmable medication reminder device on quality of life in patients with AIDS. AIDS Patient Care & Stds. 2006;20(11):773-81. Exclude Code: E3. [pmid: 17134351].
346 Wu SJ, et al. Integrating hospital medical care data with pharmaceutical education materials for diabetes self management. Studies in Health Technology & Informatics. 2006;122:660-3. Exclude Code: E. [pmid: 17102345].
347 Wydra EW. The effectiveness of a self-care management interactive multimedia module. Oncology Nursing Forum. 2001;28(9):1399-407. Exclude Code: E3. [pmid: 11683310].
348 Wylie-Rosett J, et al. Computerized weight loss intervention optimizes staff time: the clinical and cost results of a controlled clinical trial conducted in a managed care setting. Journal of the American Dietetic Association. 2001;101(10):1155-62. quiz 1163–4. Exclude Code: E. [pmid: 11678486].
349 Xavier A, et al. Cognition, interaction and ageing: an Internet workshops exploratory study. Studies in Health Technology & Informatics. 2004;103:289-95. Exclude Code: E3. [pmid: 15747933].
350 Yager J. Clinical computing: monitoring patients with eating disorders by using e-mail as an adjunct to clinical activities. Psychiatric Services. 2003;54(12):1586-8. Exclude Code: E2. [pmid: 14645794].
351 Yon BA, et al. The use of a personal digital assistant for dietary self-monitoring does not improve the validity of self-reports of energy intake. Journal of the American Dietetic Association. 2006;106(8):1256-9. Exclude Code: E3. [pmid: 16863723].
352 Young RJ, et al. Pro-active call center treatment support (PACCTS) to improve glucose control in type 2 diabetes: a randomized controlled trial. Diabetes Care. 2005;28(2):278-82. Exclude Code: E3. [pmid: 15677779].
353 Young TL, Ireson C. Effectiveness of school-based telehealth care in urban and rural elementary schools. Pediatrics. 2003;112(5):1088-94. Exclude Code: E3. [pmid: 14595051].
354 Yousef J, Lars AN. Validation of a real-time wireless telemedicine system, using bluetooth protocol and a mobile phone, for remote monitoring patient in medical practice. European Journal of Medical Research. 2005;10(6):254-62. Exclude Code: E3. [pmid: 16033715].
355 Yueh B, et al. Randomized trial of amplification strategies. Archives of Otolaryngology-Head & Neck Surgery. 2001;127(10):1197-204. Exclude Code: E3. [pmid: 11587599].
356 Zaylor C. Clinical outcomes in telepsychiatry. Journal of Telemedicine & Telecare. 1999;5(Suppl 1):S59-60. Exclude Code: E3. [pmid: 10534844].
357 Zaylor C, Whitten P, Kingsley C. Telemedicine services to a county jail. Journal of Telemedicine & Telecare. 2000;6(Suppl 1):S93-5. Exclude Code: E3. [pmid: 10793985].