# Appendix D. Literature Search Tree

[image]

* includes Medline, Cinahl, Psychinfo, ERIC, Ageline, Cochrane (See Appendix B for search strategies)

^†^ see Appendix C for details on inclusion/exclusion criteria

^††^Studies may be excluded for more than one reason

**Many studies are included in more than one Key Question