# Appendix C. Inclusion/exclusion criteria

Abstract Level

In or Out | Reason
Include | Outcome data likely; ALL DESIGNS Elderly (E) or chronically ill (CI) or medically underserved (MU)* or possible analysis as a subpopulation AND Appropriate Health information technology*
Include | Review or meta-analysis with relevant information as specified above
Include | Foreign language, meets include criteria and may have data, for use later
Uncertain (pull paper): May be relevant, can't tell from abstract
Background | Retrieve for use in introduction or discussion
Exclude | Wrong population (e.g., not elderly, underserved, or chronically ill, no subpopulation analysis)
Exclude | Wrong intervention/technology: see definition below
Exclude | No data by design (e.g., opinion, letter, editorial)
Exclude | No data by other parameter (e.g., description of technology only)
Exclude | Foreign language, no data
Exclude | No relevance to evidence report key questions
Related to topic but does not meet inclusion criteria, unspecified

Paper Level

Population

Task Order Interest | Potential Categories | Description
elderly | elderly | over 65 years of age
functionally elderly | by life experience or health concerns; need clarity/inter-observer agreement
chronically ill or disabled | chronic condition | over 1 year + benefits from ongoing monitoring or treatment
chronically ill or disabled
chronically ill or disabled | impairment | impairment in body function or structure
activity limitation | difficulty in executing activities
participation restriction | problems experienced in participating in life situations
medically underserved | medically underserved population (MUP) or medically underserved area (MUA) | study uses Bureau of Health Professions/Health Resources and Service Administration designated MUP or MUA
medically underserved | medically underserved area | region where individuals are inhibited in their ability to receive services
medically underserved group | population which is inhibited in its ability to receive services

Technology

The most challenging part of classifying the literature relating to the barriers and drivers of health information IT by the elderly, chronically ill and underserved has been in classifying the types of technology - both for the purposes of deciding which types to include in our review and also in our summarization and discussion of the results. Our inclusion / exclusion criteria are:

Include: Health information technology program where:

- Patient interacts with the technology,
- Computer / technology processes the information in some way, and
- Patient receives information in return and has access to patient-specific information.

Examples: tailored health advice; personal medical record/access; risk assessment tools, health calculators, predictive tools; interactive online support or chat groups; health games that adapt to the patient (more than simple “next page”); programs or sites with storage, indexing, retrieval, display, or advanced features (summarization and decision support).

Exclude: Health information technology program where:

- Limited or no patient or consumer driven involvement or
- Web browsing of general health information databases) or
- Patient / clinician communication without computer information support (simple videoconferencing or phone) or
- Systems where the patient interacts but doesn't receive patient-specific information back (e.g., survey - no feedback)
- Systems primarily or entirely for health professionals or caregivers

Examples: Passive monitoring; direct video or phone conferencing; general web-based content; WebMD, Medline Plus, etc.;. Education, information based only programs; surveys without feedback; frequently asked question sites; where a tele-visit replaces the face-to-face interaction with a clinician; video interaction