# Appendix B. Search Strategies

MEDLINE (1950 to November Week 2 2007)

1 exp Chronic Disease/ (173377)
2 exp Cardiovascular Diseases/ (1438368)
3 exp Lung Diseases, Obstructive/ (130454)
4 exp Diabetes Mellitus/ (220904)
5 exp Arthritis/ (157266)
6 exp Neurodegenerative Diseases/ (145561)
7 exp Cognition Disorders/ (33934)
8 exp Mental Retardation/ (67825)
9 exp Memory Disorders/ (14524)
10 exp Spinal Cord Diseases/ (75315)
11 exp Sensation Disorders/ (115283)
12 exp Dyskinesias/ (39533)
13 exp gait disorders, neurologic/ (1434)
14 exp Movement Disorders/ (68290)
15 exp paralysis/ (58765)
16 exp neuromuscular diseases/ (191261)
17 exp communication disorders/ (41578)
18 exp developmental disabilities/ (9477)
19 exp Mental Disorders/ (684932)
20 exp Neoplasms/ (1911694)
21 exp Disabled Persons/ (34321)
22 exp Nervous System Diseases/ (1539072)
23 exp hiv infections/ (169604)
24 exp Palliative Care/ (27918)
25 exp terminal care/ (31467)
26 exp home care/ (32404)
27 exp self care/ (26229)
28 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25 or 26 or 27 (5437291)
29 exp Aged/ (1674702)
30 exp Health Services for the Aged/ (11511)
31 Minority Groups/ (7142)
32 exp Ethnic Groups/ (74714)
33 exp Urban Population/ (33470)
34 Urban Health Services/ (1769)
35 Urban Health/ (11071)
36 exp Rural Health/ (18287)
37 exp Rural Health Services/ (5217)
38 exp Rural Population/ (26232)
39 exp Socioeconomic Factors/ (237725)
40 exp “Emigration and Immigration”/ (19800)
41 exp “Transients and Migrants”/ (6397)
42 exp Homeless Persons/ (4401)
43 exp vulnerable populations/ (2562)
44 exp Complementary Therapies/ (124194)
45 29 or 30 or 31 or 32 or 33 or 34 or 35 or 36 or 37 or 38 or 39 or 40 or 41 or 42 or 43 or 44 (2103285)
46 exp Information Systems/ (98874)
47 exp Telemedicine/ (8789)
48 exp Computer Systems/ (103462)
49 exp Telemetry/ (5208)
50 exp Telecommunications/ (33833)
51 exp computer assisted instruction/ (6068)
52 exp User-Computer Interface/ (14124)
53 exp video games/ (534)
54 exp computer literacy/ (1012)
55 46 or 47 or 48 or 49 or 50 or 51 or 52 or 53 or 54 (221934)
56 attitude/ or attitude to computers/ or exp attitude to health/ (215232)
57 exp Health Behavior/ (58229)
58 exp Health Education/ (102644)
59 exp Consumer Participation/ (22463)
60 exp Access to Information/ (1956)
61 56 or 57 or 58 or 59 or 60 (315151)
62 28 and 55 and 61 (4166)
63 45 and 55 and 61 (3288)
64 62 or 63 (6051)
65 limit 64 to english language (5756)
66 limit 65 to yr=“2005 - 2008” (1751)
67 limit 65 to yr=“2001 - 2004” (1819)
68 from 67 keep 1–1819 (1819)

America Association of Retired Persons Ageline (1978 to December 2007)

1 ((Health$ or patient$ or medicin$ or medical$) adj5 (Behav$ or educat$ or promot$ or enhanc$ or assess$ or evaluat$ or participat$ or informat$ or access$ or instruct$ or monitor$ or “use” or uses or using or user$ or utiliz$)).mp. [mp=abstract, descriptors, identifiers, title] (18699)
2 ((Computer$ or Information$ or internet or telephon$ or telecommun$ or communicat$) adj5 (technol$ or system$ or access$ or literac$ or interact$ or “use” or uses or using or user$ or utiliz$)).mp. [mp=abstract, descriptors, identifiers, title] (3131)
3 telemedic$.mp. [mp=abstract, descriptors, identifiers, title] (141)
4 1 and 2 (899)
5 3 or 4 (984)
6 limit 5 to yr=“1990 - 2008” (743)
7 from 6 keep 1–743 (743)

PsycINFO (1806 to February Week 4 2008)

1 exp Chronic Illness/ (12434)
2 exp Cardiovascular Disorders/ (21984)
3 exp Lung Disorders/ (1501)
4 exp Diabetes Mellitus/ (2029)
5 exp Arthritis/ (2244)
6 exp Neurodegenerative Diseases/ (24809)
7 exp Cognitive Ability/ (49657)
8 exp Mental Retardation/ (34481)
9 exp Memory Disorders/ (6470)
10 exp Sense organ disorders/ (12090)
11 exp Movement Disorders/ (12584)
12 exp paralysis/ (3316)
13 exp neuromuscular diseases/ (0)
14 exp communication disorders/ (34610)
15 exp developmental disabilities/ (7651)
16 exp Mental Disorders/ (307576)
17 exp Neoplasms/ (17431)
18 exp Disabilities/ (37156)
19 exp Nervous System Disorders/ (117832)
20 exp hiv/ (20142)
21 exp Palliative Care/ (3092)
22 exp terminal care/ (0)
23 exp home care/ (2706)
24 exp self care/ (2581)
25 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 (559924)
26 exp Aged/ (1662)
27 exp elder care/ (1877)
28 Minority Groups/ (6897)
29 exp Ethnic Groups/ (64791)
30 exp Urban environments/ (11755)
31 exp Rural Environments/ (7802)
32 exp socioeconomic status/ (26347)
33 exp Sociocultural factors/ (61600)
34 exp psychosocial factors/ (20491)
35 exp Immigration/ (7012)
36 exp human migration/ (4334)
37 exp Homeless/ (3740)
38 exp disadvantaged/ (4831)
39 exp poverty/ (3162)
40 exp at risk populations/ (21985)
41 exp alternative medicine/ (3589)
42 exp holistic health/ (1015)
43 exp “medicinal herbs and plants”/ (742)
44 26 or 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34 or 35 or 36 or 37 or 38 or 39 or 40 or 41 or 42 or 43 (203244)
45 exp Information Systems/ (11332)
46 exp Telemedicine/ (819)
47 exp Computers/ (8211)
48 exp computer applications/ (36570)
49 exp Telemetry/ (85)
50 exp computer assisted instruction/ (8563)
51 exp Human Computer Interaction/ (3852)
52 exp video games/ (1146)
53 45 or 46 or 47 or 48 or 49 or 50 or 51 or 52 (52851)
54 exp attitudes/ (199020)
55 exp Health Behavior/ (10516)
56 exp Health Education/ (9901)
57 exp Client Participation/ (826)
58 exp information literacy/ (53)
59 exp digital divide/ (102)
60 54 or 55 or 56 or 57 or 58 or 59 (214695)
61 25 and 53 and 60 (321)
62 44 and 53 and 60 (270)
63 61 or 62 (562)
64 limit 63 to yr=“1990 - 2008” (521)
65 from 64 keep 1–521 (521)

CINAHL - Cumulative Index to Nursing & Allied Health Literature (1982 to February Week 4 2008)

1 exp Chronic Disease/ (13105)
2 exp Cardiovascular Diseases/ (109186)
3 exp Lung Diseases, Obstructive/ (15894)
4 exp Diabetes Mellitus/ (30301)
5 exp Arthritis/ (11830)
6 exp Neurodegenerative Diseases/ (14138)
7 exp Cognition Disorders/ (5017)
8 exp Mental Retardation/ (6988)
9 exp Memory Disorders/ (1631)
10 exp Spinal Cord Diseases/ (2715)
11 exp Sensation Disorders/ (12372)
12 exp Dyskinesias/ (1982)
13 exp Movement Disorders/ (5096)
14 exp paralysis/ (5061)
15 exp neuromuscular diseases/ (16050)
16 exp communication disorders/ (9672)
17 exp developmental disabilities/ (1961)
18 exp Mental Disorders/ (113649)
19 exp Neoplasms/ (77516)
20 exp Disabled/ (14893)
21 exp Nervous System Diseases/ (150650)
22 exp hiv infections/ (27143)
23 exp Palliative Care/ (7652)
24 exp terminal care/ (18364)
25 exp home health care/ (20414)
26 exp self care/ (11961)
27 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25 or 26 (491273)
28 exp Aged/ (160564)
29 exp Health Services for the Aged/ (2866)
30 Minority Groups/ (3560)
31 exp Ethnic Groups/ (35621)
32 exp Urban Areas/ (5715)
33 Urban Health Services/ (300)
34 Urban Health/ (1069)
35 exp Rural Health/ (1943)
36 exp Rural Health Services/ (2130)
37 exp Rural Areas/ (6210)
38 exp Socioeconomic Factors/ (83125)
39 exp “Emigration and Immigration”/ (1717)
40 exp “Transients and Migrants”/ (676)
41 exp Homeless Persons/ (1341)
42 exp vulnerable populations/ (975)
43 exp Complementary Therapies/ (52130)
44 28 or 29 or 30 or 31 or 32 or 33 or 34 or 35 or 36 or 37 or 38 or 39 or 40 or 41 or 42 or 43 (316072)
45 exp Information Systems/ (32862)
46 computer systems/ or computer hardware/ or computer peripherals/ or computer processor/ or computer types/ or interactive voice response systems/ or software/ or communications software/ or computer graphics/ or multimedia/ (9023)
47 electronic bulletin boards/ or electronic mail/ or internet/ or wireless communications/ (11359)
48 exp Telemedicine/ (1864)
49 exp Telemetry/ (434)
50 exp computer assisted instruction/ (2868)
51 exp User-Computer Interface/ (1682)
52 exp video games/ (224)
53 exp computer literacy/ (527)
54 45 or 46 or 47 or 48 or 49 or 50 or 51 or 52 or 53 (54149)
55 attitude/ or attitude to abortion/ or attitude to adoption/ or attitude to aging/ or attitude to change/ or attitude to computers/ or exp attitude to death/ or attitude to disability/ or exp attitude to health/ or exp attitude to illness/ or attitude to life/ or attitude to obesity/ or attitude to pregnancy/ or attitude to risk/ or exp attitude to sexuality/ or consumer attitudes/ or cultural bias/ or cultural sensitivity/ or exp family attitudes/ or gender bias/ or patient attitudes/ or exp personal satisfaction/ or exp social attitudes/ or uncertainty/ (81195)
56 exp Health Behavior/ (22660)
57 exp Health Education/ (46582)
58 exp Consumer Participation/ (4961)
59 exp Access to Information/ (5087)
60 55 or 56 or 57 or 58 or 59 (136133)
61 27 and 54 and 60 (1444)
62 44 and 54 and 60 (1117)
63 61 or 62 (2094)
64 limit 63 to english language (2065)
65 limit 64 to yr=“1990 - 2008” (2052)
66 limit 65 to yr=“1990 - 2003” (832)
67 limit 65 to yr=“2004 - 2008” (1220)
68 from 67 keep 1–1220 (1220)

EBM Reviews - Cochrane Database of Systematic Reviews (1st Quarter 2008)

1 ((health$ or patient$ or home or homes or ((self or selves) adj2 (help$ or care or caring or cares))) adj5 (internet$ or telemedic$ or telehealth$ or web-base$ or (information$ adj2 (technol$ or system$ or computer$)))).mp. (73)
2 from 1 keep 1–73 (73)

EBM Reviews - Cochrane Central Register of Controlled Trials (1st Quarter 2008)

1 ((health$ or patient$ or home or homes or ((self or selves) adj2 (help$ or care or caring or cares))) adj5 (internet$ or telemedic$ or telehealth$ or web-base$ or (information$ adj2 (technol$ or system$ or computer$)))).mp. (498)
2 from 1 keep 1–498 (498)