# Appendix A. Technical Expert Panel Members

S. Ann Becker, PhD Professor in College of Business and College of Engineering, Florida Institute of Technology, Melbourne, Florida

Patty Flatley Brennan, RN, PhD Moehlman Bascom Professor of Nursing & Industrial Engineering, School of Nursing & College of Engineering, University of Wisconsin-Madison

M. Chris Gibbons, MD, MPH Assistant Professor, Associate Director, Johns Hopkins Urban Health Institute

Jennie Chin Hansen, RN, BS, MS AARP Board Member and a Senior Fellow at the University of California, San Francisco, Center for the Health Professions

Warren Jones, MD Executive Director, Mississippi Institute for the Improvement of Geographical Minority Health; Distinguished Professor of Health Policy and Senior Health Policy Advisor at the University of Mississippi Medical Center

Tom Landauer, PhD Professor in the Department of Psychology of the University of Colorado, Founder of Knowledge Analysis Technologies (now Pearson Knowledge Technologies)

Anna M. Nápoles-Springer, PhD Assistant Adjunct Professor, Department of Medicine, University of California at San Francisco

John Santa, MD, MPH Adjunct Associate Professor in the Center for Evidence-based Policy at Oregon Health and Science University