# Appendixes

Appendix A. Technical Expert Panel Members

Appendix B. Search Strategies

Appendix C. Inclusion/exclusion criteria

Appendix D. Literature Search Tree

Appendix E. Excluded Studies List

Appendix F. Quality Assessment Criteria

Appendix G. Peer Reviewers

Appendix H. Data Abstraction Table with References

Appendix I. Study Quality Assessment Table with References