# List of Acronyms and Abbreviations

AFP | Alpha fetoprotein
AHRQ | Agency for Healthcare Research and Quality
ALT | Alanine aminotransferase
ARD | Absolute risk difference
AST | Aspartate aminotransferase
BCP | Basal core promoter
BEHoLD | Benefits of Entecavir for Hepatitis B Liver Disease
BMI | Body mass index
CD | Cluster of differentiation
CHB | Chronic hepatitis B
CI | Confidence interval
CK | Creatine kinase
DNA | Deoxyribonucleic Acid
ELISA | Enzyme-Linked ImmunoSorbent Assay
EPC | Evidence-based practice center
FDA | Food and Drug Administration
HAI | Histological activity index
HBeAg | Hepatitis B “e” antigen
HbsAg | Hepatitis B surface antigen
HBV | Hepatitis B virus
HCC | Hepatocellular carcinoma
HCV | Hepatitis C virus
HDV | Hepatitis delta virus
HIV | Human immunodeficiency virus
HR | Hazard ratio
MACS | Multicenter AIDS cohort study
MU | Million units
NIH | National Institutes of Health
PC | Precore
PCR | Polymerase chain reaction
OR | Odds ratio
RCT | Randomized controlled trial
RR | Relative risk
RT-PCR | Reverse transcriptase - polymerase chain reaction
SD | Standard deviation
TEP | Technical expert panel
ULN | Upper limit of normal
WBC | White blood cells