# References and Included Studies

(Note that there is a separate set of references at the end of the evidence tables in Appendix E and reference numbers differ from those in the text of the report.)

1 Lok AS, McMahon BJ. Chronic hepatitis B. Hepatology. Feb. 2007;45(2):507-39. [pmid: 17256718].
2 National Center for Health Statistics (U.S.). Health, United States, 2006, with chartbook on trends in the health of Americans. Hyattsville, Md.: Dept. of Health and Human Services, Centers for Disease Control and Prevention, National Center for Health Statistics; 2006.
3 Wasley A, Grytdal S, Gallagher K. Surveillance for acute viral hepatitis—United States, 2006. MMWR Surveill Summ. Mar 21. 2008;57(2):1-24. [pmid: 18354374].
4 Minino AM, Heron MP, Murphy SL, et al. Deaths: final data for 2004. Natl Vital Stat Rep. Aug 21. 2007;55(19):1-119. [pmid: 17867520].
5 Pungpapong S, Kim WR, Poterucha JJ. Natural history of hepatitis B virus infection: an update for clinicians. Mayo Clin Proc. Aug. 2007;82(8):967-75. [pmid: 17673066].
6 Hoofnagle JH, Doo E, Liang TJ, et al. Management of hepatitis B: summary of a clinical research workshop. Hepatology. Apr. 2007;45(4):1056-75. [pmid: 17393513].
7 Keeffe EB, Marcellin P. New and emerging treatment of chronic hepatitis B. Clin Gastroenterol Hepatol. Mar. 2007;5(3):285-94. [pmid: 17218162].
8 De Clercq E. The discovery of antiviral agents: Ten different compounds, ten different stories. Med Res Rev 2008 Apr 25.
9 Sherman M, Shafran S, Burak K, et al. Management of chronic hepatitis B: consensus guidelines. Can J Gastroenterol. Jun. 2007;21(Suppl C):5C-24C.
10 Hadziyannis SJ, Tassopoulos NC, Heathcote EJ, et al. Long-term therapy with adefovir dipivoxil for HBeAg-negative chronic hepatitis B. N Engl J Med. Jun 30. 2005;352(26):2673-81. [pmid: 15987916].
11 Ghany M, Liang TJ. Drug targets and molecular mechanisms of drug resistance in chronic hepatitis B. Gastroenterology. Apr. 2007;132(4):1574-85. [pmid: 17408658].
12 Cochrane Collaboration. The Cochrane library. Update Software Ltd. Available at: http://www3.interscience.wiley.com/cgi-bin/mrwhome/106568753/HOME
13 United States. Food and Drug Administration. MedWatch. MedWatch online voluntary reporting form (3500). [Rockville, Md.]: Food and Drug Administration, MedWatch; 2002.
14 Great Britain. Committee on Safety of Medicines., Great Britain. Medicines Control Agency., Great Britain. Medicines and Healthcare products Regulatory Agency. Current problems in pharmacovigilance. [London: The Agency.
15 European Agency for the Evaluation of Medicinal Products. European public assessment reports (EPARs). London: European Agency for the Evaluation of Medicinal Products; 1995.
16 Fontaine H, Petitprez K, Roudot-Thoraval F, et al. Guidelines for the diagnosis of uncomplicated cirrhosis. Gastroenterol Clin Biol. May. 2007;31(5):504-9. [pmid: 17541342].
17 U.S. Food and Drug Administration (FDA) Center for Drug Evaluation and Research (CDER): Center for Drug Evaluation and Research (CDER).
18 ClinicalTrials.gov; information about federally and privately supported clinical research in human volunteers. Bethesda, Md.: U.S. National Library of Medicine; 2002.
19 Abiad H, Ramani R, Currie JB, et al. The natural history of hepatitis D virus infection in Illinois state facilities for the developmentally disabled. American Journal of Gastroenterology. Feb. 2001;96(2):534-40. [pmid: 11232702].
20 Amin J, Dore GJ, O'Connell DL, et al. Cancer incidence in people with hepatitis B or C infection: a large community-based linkage study. Journal of Hepatology. Aug. 2006;45(2):197-203. [pmid: 16684579].
21 Beasley RP, Hwang LY, Lin CC, et al. Hepatocellular carcinoma and hepatitis B virus. A prospective study of 22 707 men in Taiwan. Lancet. Nov 21. 1981;2(8256):1129-33. [pmid: 6118576].
22 Chan HL, Tse CH, Mo F, et al. High viral load and hepatitis B virus subgenotype ce are associated with increased risk of hepatocellular carcinoma. J Clin Oncol. Jan 10. 2008;26(2):177-82. [pmid: 18182659].
23 Chen CJ, Yang HI, Su J, et al. Risk of hepatocellular carcinoma across a biological gradient of serum hepatitis B virus DNA level. JAMA. Jan 4. 2006;295(1):65-73. [pmid: 16391218].
24 Chen G, Lin W, Shen F, et al. Chronic hepatitis B virus infection and mortality from non-liver causes: results from the Haimen City cohort study. International Journal of Epidemiology. Feb. 2005;34(1):132-7. [pmid: 15659459].
25 Chen G, Lin W, Shen F, et al. Past HBV viral load as predictor of mortality and morbidity from HCC and chronic liver disease in a prospective study. American Journal of Gastroenterology. Aug. 2006;101(8):1797-803. [pmid: 16817842].
26 Chen JG, Kuang SY, Egner PA, et al. Acceleration to death from liver cancer in people with hepatitis B viral mutations detected in plasma by mass spectrometry. Cancer Epidemiology, Biomarkers & Prevention. Jun. 2007;16(6):1213-8.
27 Crook PD, Jones ME, Hall AJ, et al. Mortality of hepatitis B surface antigen-positive blood donors in England and Wales. International Journal of Epidemiology. Feb. 2003;32(1):118-24. [pmid: 12690022].
28 Evans AA, Chen G, Ross EA, et al. Eight-year follow-up of the 90,000-person Haimen City cohort: I. Hepatocellular carcinoma mortality, risk factors, and gender differences. Cancer Epidemiology, Biomarkers & Prevention. Apr. 2002;11(4):369-76.
29 Iloeje UH, Yang HI, Su J, et al. Predicting cirrhosis risk based on the level of circulating hepatitis B viral load.[see comment]. Gastroenterology. Mar. 2006;130(3):678-86. [pmid: 16530509].
30 Jee SH, Ohrr H, Sull JW, et al. Cigarette smoking, alcohol drinking, hepatitis B, and risk for hepatocellular carcinoma in Korea. Journal of the National Cancer Institute. Dec 15. 2004;96(24):1851-6. [pmid: 15601641].
31 Konopnicki D, Mocroft A, de Wit S, et al. Hepatitis B and HIV: prevalence, AIDS progression, response to highly active antiretroviral therapy and increased mortality in the EuroSIDA cohort.[see comment]. AIDS. Mar 24. 2005;19(6):593-601. [pmid: 15802978].
32 Lam CM, Chan AO, Ho P, et al. Different presentation of hepatitis B-related hepatocellular carcinoma in a cohort of 1863 young and old patients - implications for screening. Alimentary Pharmacology & Therapeutics. Apr 1. 2004;19(7):771-7. [pmid: 15043518].
33 Livingston SE, Simonetti JP, McMahon BJ, et al. Hepatitis B virus genotypes in Alaska Native people with hepatocellular carcinoma: preponderance of genotype F.[see comment]. Journal of Infectious Diseases. Jan 1. 2007;195(1):5-11. [pmid: 17152003].
34 London WT, Evans AA, McGlynn K, et al. Viral, host and environmental risk factors for hepatocellular carcinoma: a prospective study in Haimen City, China. Intervirology. 1995;38(34):155-61. [pmid: 8682610].
35 McMahon BJ, Alberts SR, Wainwright RB, et al. Hepatitis B-related sequelae. Prospective study in 1400 hepatitis B surface antigen-positive Alaska native carriers. Archives of Internal Medicine. May. 1990;150(5):1051-4. [pmid: 2158773].
36 McMahon BJ, Bulkow L, Harpster A, et al. Screening for hepatocellular carcinoma in Alaska natives infected with chronic hepatitis B: a 16-year population-based study. Hepatology. Oct. 2000;32(4 Pt 1):842-6. [pmid: 11003632].
37 McMahon BJ, Holck P, Bulkow L, et al. Serologic and clinical outcomes of 1536 Alaska Natives chronically infected with hepatitis B virus.[see comment]. Annals of Internal Medicine. Nov 6. 2001;135(9):759-68. [pmid: 11694101].
38 Mori M, Hara M, Wada I, et al. Prospective study of hepatitis B and C viral infections, cigarette smoking, alcohol consumption, and other factors associated with hepatocellular carcinoma risk in Japan. American Journal of Epidemiology. Jan 15. 2000;151(2):131-9. [pmid: 10645815].
39 Nomura A, Stemmermann GN, Chyou PH, et al. Hepatitis B and C virus serologies among Japanese Americans with hepatocellular carcinoma. Journal of Infectious Diseases. Jun. 1996;173(6):1474-6. [pmid: 8648223].
40 Norman JE, Beebe GW, Hoofnagle JH, et al. Mortality follow-up of the 1942 epidemic of hepatitis B in the U.S. Army. Hepatology. Oct. 1993;18(4):790-7. [pmid: 8406352].
41 Ribes J, Cleries R, Rubio A, et al. Cofactors associated with liver disease mortality in an HBsAg-positive Mediterranean cohort: 20 years of follow-up. International Journal of Cancer. Aug 1. 2006;119(3):687-94.
42 Sherman M, Peltekian KM, Lee C. Screening for hepatocellular carcinoma in chronic carriers of hepatitis B virus: incidence and prevalence of hepatocellular carcinoma in a North American urban population. Hepatology. Aug. 1995;22(2):432-8. [pmid: 7543434].
43 Tanaka H, Tsukuma H, Yamano H, et al. Prospective study on the risk of hepatocellular carcinoma among hepatitis C virus-positive blood donors focusing on demographic factors, alanine aminotransferase level at donation and interaction with hepatitis B virus. International Journal of Cancer. Dec 20. 2004;112(6):1075-80.
44 Thio CL, Seaberg EC, Skolasky R Jr, et al. HIV-1, hepatitis B virus, and risk of liver-related mortality in the Multicenter Cohort Study (MACS). Lancet. Dec 14. 2002;360(9349):1921-6. [pmid: 12493258].
45 Tokudome S, Ikeda M, Matsushita K, et al. Hepatocellular carcinoma among female Japanese hepatitis B virus carriers. Hepato-Gastroenterology. Dec. 1987;34(6):246-8. [pmid: 2828208].
46 Tong MJ, Blatt LM, Kao VW, et al. Surveillance for hepatocellular carcinoma in patients with chronic viral hepatitis in the United States of America. Journal of Gastroenterology & Hepatology. May. 2001;16(5):553-9. [pmid: 11350553].
47 Tong MJ, Blatt LM, Tyson KB, et al. Death from liver disease and development of hepatocellular carcinoma in patients with chronic Hepatitis B virus infection: a prospective study. Gastroenterology & Hepatology. Jan. 2006;2(1):41-7.
48 Tong MJ, Blatt LM, Kao JH, et al. Precore/basal core promoter mutants and hepatitis B viral DNA levels as predictors for liver deaths and hepatocellular carcinoma. World J Gastroenterol. Nov 7. 2006;12(41):6620-6. [pmid: 17075974].
49 Tong MJ, Blatt LM, Kao JH, et al. Basal core promoter T1762/A1764 and precore A1896 gene mutations in hepatitis B surface antigen-positive hepatocellular carcinoma: a comparison with chronic carriers. Liver Int. Dec. 2007;27(10):1356-63. [pmid: 17900245].
50 Wang LY, You SL, Lu SN, et al. Risk of hepatocellular carcinoma and habits of alcohol drinking, betel quid chewing and cigarette smoking: a cohort of 2416 HBsAg-seropositive and 9421 HBsAg-seronegative male residents in Taiwan. Cancer Causes & Control. Apr. 2003;14(3):241-50. [pmid: 12814203].
51 Weissberg JI, Andres LL, Smith CI, et al. Survival in chronic hepatitis B. An analysis of 379 patients. Ann Intern Med. Nov. 1984;101(5):613-6. [pmid: 6486592].
52 Yang HI, Lu SN, Liaw YF, et al. Hepatitis B e antigen and the risk of hepatocellular carcinoma. New England Journal of Medicine. Jul 18. 2002;347(3):168-74. [pmid: 12124405].
53 Yu MW, Hsu FC, Sheen IS, et al. Prospective study of hepatocellular carcinoma and liver cirrhosis in asymptomatic chronic hepatitis B virus carriers. American Journal of Epidemiology. Jun 1. 1997;145(11):1039-47. [pmid: 9169913].
54 Yu MW, Yang SY, Chiu YH, et al. A p53 genetic polymorphism as a modulator of hepatocellular carcinoma risk in relation to chronic liver disease, familial tendency, and cigarette smoking in hepatitis B carriers. Hepatology. Mar. 1999;29(3):697-702. [pmid: 10051470].
55 Yu MW, Yeh SH, Chen PJ, et al. Hepatitis B virus genotype and DNA level and hepatocellular carcinoma: a prospective study in men.[see comment]. Journal of the National Cancer Institute. Feb 16. 2005;97(4):265-72. [pmid: 15713961].
56 Yuen MF, Yuan HJ, Wong DK, et al. Prognostic determinants for chronic hepatitis B in Asians: therapeutic implications. Gut. Nov. 2005;54(11):1610-4. [pmid: 15871997].
57 Chou YC, Yu MW, Wu CF, et al. Temporal relationship between hepatitis B virus enhancer II/basal core promoter sequence variation and risk of hepatocellular carcinoma. Gut. Jan. 2008;57(1):91-7. [pmid: 17502344].
58 Iloeje UH, Yang HI, Jen CL, et al. Risk and predictors of mortality associated with chronic hepatitis B infection. Clin Gastroenterol Hepatol. Aug. 2007;5(8):921-31. [pmid: 17678844].
59 Wu CF, Yu MW, Lin CL, et al. Long-term tracking of hepatitis B viral load and the relationship with risk for hepatocellular carcinoma in men. Carcinogenesis. Jan. 2008;29(1):106-12. [pmid: 17999990].
60 Chu CM. Natural history of chronic hepatitis B virus infection in adults with emphasis on the occurrence of cirrhosis and hepatocellular carcinoma. J Gastroenterol Hepatol. May. 2000;15(Suppl):E25-30. [pmid: 10921378].
61 Janssen HL, Gerken G, Carreno V, et al. Interferon alfa for chronic hepatitis B infection: increased efficacy of prolonged treatment. The European Concerted Action on Viral Hepatitis (EUROHEP). Hepatology. Jul. 1999;30(1):238-43. [pmid: 10385662].
62 Schalm SW, Heathcote J, Cianciara J, et al. Lamivudine and alpha interferon combination treatment of patients with chronic hepatitis B infection: a randomised trial. Gut. Apr. 2000;46(4):562-8. [pmid: 10716688].
63 Barbaro G, Zechini F, Pellicelli AM, et al. Long-term efficacy of interferon alpha-2b and lamivudine in combination compared to lamivudine monotherapy in patients with chronic hepatitis B. An Italian multicenter, randomized trial. J Hepatol. Sep. 2001;35(3):406-11. [pmid: 11592603].
64 Perrillo RP, Lai CL, Liaw YF, et al. Predictors of HBeAg loss after lamivudine treatment for chronic hepatitis B. Hepatology. Jul. 2002;36(1):186-94. [pmid: 12085364].
65 Wai CT, Chu CJ, Hussain M, et al. HBV genotype B is associated with better response to interferon therapy in HBeAg(+) chronic hepatitis than genotype C. Hepatology. Dec. 2002;36(6):1425-30. [pmid: 12447868].
66 Chung YH, Song BC, Lee GC, et al. Individualization of interferon therapy using serum hepatitis B virus DNA to reduce viral relapse in patients with chronic hepatitis B: a randomized controlled trial. Eur J Gastroenterol Hepatol. May. 2003;15(5):489-93. [pmid: 12702905].
67 Schiff ER, Dienstag JL, Karayalcin S, et al. Lamivudine and 24 weeks of lamivudine/interferon combination therapy for hepatitis B e antigen-positive chronic hepatitis B in interferon nonresponders. J Hepatol. Jun. 2003;38(6):818-26. [pmid: 12763376].
68 Yalcin K, Degertekin H, Yildiz F, et al. Comparison of 12-month courses of interferon-alpha-2b-lamivudine combination therapy and interferon-alpha-2b monotherapy among patients with untreated chronic hepatitis B. Clin Infect Dis. Jun 15. 2003;36(12):1516-22. [pmid: 12802750].
69 Niederau C, Heintges T, Niederau M, et al. Prospective randomized controlled trial of sequential treatment with corticoids and alpha-interferon versus treatment with interferon alone in patients with chronic active hepatitis B. Eur J Med. Nov. 1992;1(7):396-402. [pmid: 1341478].
70 Robson SC, Brice E, van Rensburg C, et al. Safety and efficacy of interferon alpha-2b following prednisone withdrawal in the treatment of chronic viral hepatitis B. A case-controlled, randomised study. S Afr Med J. Nov. 1992;82(5):317-20. [pmid: 1448711].
71 Akarca US, Ersoz G, Gunsar F, et al. Interferon-lamivudine combination is no better than lamivudine alone in anti-HBe-positive chronic hepatitis B. Antivir Ther. Jun. 2004;9(3):325-34. [pmid: 15259895].
72 Jang MK, Chung YH, Choi MH, et al. Combination of alpha-interferon with lamivudine reduces viral breakthrough during long-term therapy. J Gastroenterol Hepatol. Dec. 2004;19(12):1363-8. [pmid: 15610309].
73 Lok AS, Wu PC, Lai CL, et al. A controlled trial of interferon with or without prednisone priming for chronic hepatitis B. Gastroenterology. Jun. 1992;102(6):2091-7. [pmid: 1587429].
74 Economou M, Manolakopoulos S, Trikalinos TA, et al. Interferon-alpha plus lamivudine vs lamivudine reduces breakthroughs, but does not affect sustained response in HBeAg negative chronic hepatitis B. World J Gastroenterol. Oct 7. 2005;11(37):5882-7. [pmid: 16270403].
75 Sarin SK, Kumar M, Kumar R, et al. Higher efficacy of sequential therapy with interferon-alpha and lamivudine combination compared to lamivudine monotherapy in HBeAg positive chronic hepatitis B patients. Am J Gastroenterol. Nov. 2005;100(11):2463-71. [pmid: 16279901].
76 Shi M, Wang RS, Zhang H, et al. Sequential treatment with lamivudine and interferon-alpha monotherapies in hepatitis B e antigen-negative Chinese patients and its suppression of lamivudine-resistant mutations. J Antimicrob Chemother. Nov. 2006;58(5):1031-5. [pmid: 16987866].
77 Scotto G, Palumbo E, Fazio V, et al. Efficacy and tolerability of lamivudine alone versus lamivudine plus alpha-interferon for treatment of chronic active hepatitis B in patients with a precore-mutant variant. Infez Med. Sep. 2006;14(3):145-51. [pmid: 17127828].
78 Lu HY, Zhuang LW, Yu YY, et al. Intrahepatic HBV DNA as a predictor of antivirus treatment efficacy in HBeAg-positive chronic hepatitis B patients. World J Gastroenterol. May 28. 2007;13(20):2878-82. [pmid: 17569128].
79 Akyuz F, Kaymakoglu S, Demir K, et al. Lamivudine monotherapy and lamivudine plus interferon alpha combination therapy in HBeAg negative chronic hepatitis B not responding to previous interferon alpha monotherapy. Acta Gastroenterol Belg. Jan–Mar. 2007;70(1):20-4. [pmid: 17619534].
80 Perez V, Tanno H, Villamil F, et al. Recombinant interferon alfa-2b following prednisone withdrawal in the treatment of chronic type B hepatitis. J Hepatol. 1990;11(Suppl 1):S113-7. [pmid: 2079567].
81 Hadziyannis S, Bramou T, Makris A, et al. Interferon alfa-2b treatment of HBeAg negative/serum HBV DNA positive chronic active hepatitis type B. J Hepatol. 1990;11(Suppl 1):S133-6. [pmid: 2079571].
82 Muller R, Baumgarten R, Markus R, et al. Treatment of chronic hepatitis B with interferon alfa-2b. J Hepatol. 1990;11(Suppl 1):S137-40. [pmid: 2079572].
83 Waked I, Amin M, Abd el Fattah S, et al. Experience with interferon in chronic hepatitis B in Egypt. J Chemother. Oct. 1990;2(5):310-8. [pmid: 2090770].
84 Perrillo RP, Schiff ER, Davis GL, et al. A randomized, controlled trial of interferon alfa-2b alone and after prednisone withdrawal for the treatment of chronic hepatitis B. The Hepatitis Interventional Therapy Group. N Engl J Med. Aug 2. 1990;323(5):295-301. [pmid: 2195346].
85 Zarski JP, Causse X, Cohard M, et al. A randomized, controlled trial of interferon alfa-2b alone and with simultaneous prednisone for the treatment of chronic hepatitis B. French Multicenter Group. J Hepatol. Jun. 1994;20(6):735-41. [pmid: 7930473].
86 Reichen J, Bianchi L, Frei PC, et al. Efficacy of steroid withdrawal and low-dose interferon treatment in chronic active hepatitis B. Results of a randomized multicenter trial. Swiss Association for the Study of the Liver. J Hepatol. Feb. 1994;20(2):168-74. [pmid: 8006396].
87 Di Bisceglie AM, Fong TL, Fried MW, et al. A randomized, controlled trial of recombinant alpha-interferon therapy for chronic hepatitis B. Am J Gastroenterol. Nov. 1993;88(11):1887-92. [pmid: 8237937].
88 Perez V, Findor J, Tanno H, et al. A controlled trial of high dose interferon, alone and after prednisone withdrawal, in the treatment of chronic hepatitis B: long term follow up. Gut. 1993;34(2 Suppl):S91-4. [pmid: 8314497].
89 Muller R, Baumgarten R, Markus R, et al. Low dose alpha interferon treatment in chronic hepatitis B virus infection. Gut. 1993;34(2 Suppl):S97-8. [pmid: 8314499].
90 Lopez-Alcorocho JM, Bartolome J, Cotonat T, et al. Efficacy of prolonged interferon-alpha treatment in chronic hepatitis B patients with HBeAb: comparison between 6 and 12 months of therapy. J Viral Hepat. 1997;4(Suppl 1):27-32. [pmid: 9097275].
91 Lampertico P, Del Ninno E, Manzin A, et al. A randomized, controlled trial of a 24-month course of interferon alfa 2b in patients with chronic hepatitis B who had hepatitis B virus DNA without hepatitis B e antigen in serum. Hepatology. Dec. 1997;26(6):1621-5. [pmid: 9398007].
92 Mutimer D, Naoumov N, Honkoop P, et al. Combination alpha-interferon and lamivudine therapy for alpha-interferon-resistant chronic hepatitis B infection: results of a pilot study. J Hepatol. Jun. 1998;28(6):923-9. [pmid: 9672165].
93 Bonino F, Marcellin P, Lau GK, et al. Predicting response to peginterferon alpha-2a, lamivudine and the two combined for HBeAg-negative chronic hepatitis B. Gut. May. 2007;56(5):699-705. [pmid: 17127704].
94 Cooksley WG, Piratvisuth T, Lee SD, et al. Peginterferon alpha-2a (40 kDa): an advance in the treatment of hepatitis B e antigen-positive chronic hepatitis B. J Viral Hepat. Jul. 2003;10(4):298-305. [pmid: 12823597].
95 Marcellin P, Lau GK, Bonino F, et al. Peginterferon alfa-2a alone, lamivudine alone, and the two in combination in patients with HBeAg-negative chronic hepatitis B. N Engl J Med. Sep 16. 2004;351(12):1206-17. [pmid: 15371578].
96 Lau GK, Piratvisuth T, Luo KX, et al. Peginterferon Alfa-2a, lamivudine, and the combination for HBeAg-positive chronic hepatitis B. N Engl J Med. Jun 30. 2005;352(26):2682-95. [pmid: 15987917].
97 Cindoruk M, Karakan T, Unal S. Hepatic steatosis has no impact on the outcome of treatment in patients with chronic hepatitis B infection. J Clin Gastroenterol. May–Jun. 2007;41(5):513-7. [pmid: 17450036].
98 Flink HJ, van Zonneveld M, Hansen BE, et al. Treatment with Peg-interferon alpha-2b for HBeAg-positive chronic hepatitis B: HBsAg loss is associated with HBV genotype. Am J Gastroenterol. Feb. 2006;101(2):297-303. [pmid: 16454834].
99 Janssen HL, van Zonneveld M, Senturk H, et al. Pegylated interferon alfa-2b alone or in combination with lamivudine for HBeAg-positive chronic hepatitis B: a randomised trial. Lancet. Jan 8–14. 2005;365(9454):123-9. [pmid: 15639293].
100 Buster EH, Hansen BE, Buti M, et al. Peginterferon alpha-2b is safe and effective in HBeAg-positive chronic hepatitis B patients with advanced fibrosis. Hepatology. Aug. 2007;46(2):388-94. [pmid: 17604363].
101 ter Borg MJ, van Zonneveld M, Zeuzem S, et al. Patterns of viral decline during PEG-interferon alpha-2b therapy in HBeAg-positive chronic hepatitis B: relation to treatment response. Hepatology. Sep. 2006;44(3):721-7. [pmid: 16941701].
102 Flink HJ, Hansen BE, Heathcote EJ, et al. Successful treatment with peginterferon alfa-2b of HBeAg-positive HBV non-responders to standard interferon or lamivudine. Am J Gastroenterol. Nov. 2006;101(11):2523-9. [pmid: 17029610].
103 van Zonneveld M, Flink HJ, Verhey E, et al. The safety of pegylated interferon alpha-2b in the treatment of chronic hepatitis B: predictive factors for dose reduction and treatment discontinuation. Aliment Pharmacol Ther. May 1. 2005;21(9):1163-71. [pmid: 15854180].
104 Flink HJ, Sprengers D, Hansen BE, et al. Flares in chronic hepatitis B patients induced by the host or the virus? Relation to treatment response during Peg-interferon {alpha}-2b therapy. Gut. Nov. 2005;54(11):1604-9. [pmid: 15923670].
105 van Zonneveld M, Zondervan PE, Cakaloglu Y, et al. Peg-interferon improves liver histology in patients with HBeAg-positive chronic hepatitis B: no additional benefit of combination with lamivudine. Liver Int. May. 2006;26(4):399-405. [pmid: 16629642].
106 Chan HL, Hui AY, Wong VW, et al. Long-term follow-up of peginterferon and lamivudine combination treatment in HBeAg-positive chronic hepatitis B. Hepatology. Jun. 2005;41(6):1357-64. [pmid: 15880608].
107 Chan HL, Leung NW, Hui AY, et al. A randomized, controlled trial of combination therapy for chronic hepatitis B: comparing pegylated interferon-alpha2b and lamivudine with lamivudine alone. Ann Intern Med. Feb 15. 2005;142(4):240-50. [pmid: 15710957].
108 Chan HL, Tse AM, Zhang MD, et al. Genetic polymorphisms of interleukin-1-beta in association with sustained response to anti-viral treatment in chronic hepatitis B in Chinese. Aliment Pharmacol Ther. Jun 15. 2006;23(12):1703-11. [pmid: 16817913].
109 Zhao H, Kurbanov F, Wan MB, et al. Genotype B and younger patient age associated with better response to low-dose therapy: a trial with pegylated/nonpegylated interferon-alpha-2b for hepatitis B e antigen-positive patients with chronic hepatitis B in China. Clin Infect Dis. Feb 15. 2007;44(4):541-8. [pmid: 17243057].
110 Hadziyannis SJ, Tassopoulos NC, Heathcote EJ, et al. Adefovir dipivoxil for the treatment of hepatitis B e antigen-negative chronic hepatitis B. N Engl J Med. Feb 27. 2003;348(9):800-7. [pmid: 12606734].
111 Hadziyannis SJ, Tassopoulos NC, Heathcote EJ, et al. Long-term therapy with adefovir dipivoxil for HBeAg-negative chronic hepatitis B for up to 5 years. Gastroenterology. Dec. 2006;131(6):1743-51. [pmid: 17087951].
112 Marcellin P, Chang TT, Lim SG, et al. Adefovir dipivoxil for the treatment of hepatitis B e antigen-positive chronic hepatitis B. N Engl J Med. Feb 27. 2003;348(9):808-16. [pmid: 12606735].
113 Zeng M, Mao Y, Yao G, et al. A double-blind randomized trial of adefovir dipivoxil in Chinese subjects with HBeAg-positive chronic hepatitis B. Hepatology. Jul. 2006;44(1):108-16. [pmid: 16799983].
114 Westland C, Delaney Wt, Yang H, et al. Hepatitis B virus genotypes and virologic response in 694 patients in phase III studies of adefovir dipivoxil. Gastroenterology. Jul. 2003;125(1):107-16. [pmid: 12851876].
115 Westland CE, Yang H, Delaney WEt, et al. Week 48 resistance surveillance in two phase 3 clinical studies of adefovir dipivoxil for chronic hepatitis B. Hepatology. Jul. 2003;38(1):96-103. [pmid: 12829991].
116 Izzedine H, Hulot JS, Launay-Vacher V, et al. Renal safety of adefovir dipivoxil in patients with chronic hepatitis B: two double-blind, randomized, placebo-controlled studies. Kidney Int. Sep. 2004;66(3):1153-8. [pmid: 15327411].
117 Perrillo R, Hann HW, Mutimer D, et al. Adefovir dipivoxil added to ongoing lamivudine in chronic hepatitis B with YMDD mutant hepatitis B virus. Gastroenterology. Jan. 2004;126(1):81-90. [pmid: 14699490].
118 Akyildiz M, Gunsar F, Ersoz G, et al. Adefovir dipivoxil alone or in combination with lamivudine for three months in patients with lamivudine resistant compensated chronic hepatitis B. Dig Dis Sci. Dec. 2007;52(12):3444-7. [pmid: 17431777].
119 Peters MG, Hann Hw H, Martin P, et al. Adefovir dipivoxil alone or in combination with lamivudine in patients with lamivudine-resistant chronic hepatitis B. Gastroenterology. Jan. 2004;126(1):91-101. [pmid: 14699491].
120 Chan HL, Heathcote EJ, Marcellin P, et al. Treatment of hepatitis B e antigen positive chronic hepatitis with telbivudine or adefovir: a randomized trial. Ann Intern Med. Dec 4. 2007;147(11):745-54. [pmid: 17909201].
121 Lai CL, Shouval D, Lok AS, et al. Entecavir versus lamivudine for patients with HBeAg-negative chronic hepatitis B. N Engl J Med. Mar 9. 2006;354(10):1011-20. [pmid: 16525138].
122 Chang TT, Gish RG, de Man R, et al. A comparison of entecavir and lamivudine for HBeAg-positive chronic hepatitis B. N Engl J Med. Mar 9. 2006;354(10):1001-10. [pmid: 16525137].
123 Lai CL, Rosmawati M, Lao J, et al. Entecavir is superior to lamivudine in reducing hepatitis B virus DNA in patients with chronic hepatitis B infection. Gastroenterology. Dec. 2002;123(6):1831-8. [pmid: 12454840].
124 Chang TT, Gish RG, Hadziyannis SJ, et al. A dose-ranging study of the efficacy and tolerability of entecavir in Lamivudine-refractory chronic hepatitis B patients. Gastroenterology. Oct. 2005;129(4):1198-209. [pmid: 16230074].
125 Sherman M, Yurdaydin C, Sollano J, et al. Entecavir for treatment of lamivudine-refractory, HBeAg-positive chronic hepatitis B. Gastroenterology. Jun. 2006;130(7):2039-49. [pmid: 16762627].
126 Gish RG, Lok AS, Chang TT, et al. Entecavir therapy for up to 96 weeks in patients with HBeAg-positive chronic hepatitis B. Gastroenterology. Nov. 2007;133(5):1437-44. [pmid: 17983800].
127 Lai CL, Leung N, Teo EK, et al. A 1-year trial of telbivudine, lamivudine, and the combination in patients with hepatitis B e antigen-positive chronic hepatitis B. Gastroenterology. Aug. 2005;129(2):528-36. [pmid: 16083710].
128 Kweon YO, Goodman ZD, Dienstag JL, et al. Decreasing fibrogenesis: an immunohistochemical study of paired liver biopsies following lamivudine therapy for chronic hepatitis B. J Hepatol. Dec. 2001;35(6):749-55. [pmid: 11738102].
129 Ke CZ, Chen Y, Gong ZJ, et al. Dynamic changes of HBV DNA in serum and peripheral blood mononuclear cells of chronic hepatitis patients after lamivudine treatment. World J Gastroenterol. Jul 7. 2006;12(25):4061-3. [pmid: 16810760].
130 Yuen MF, Chow DH, Tsui K, et al. Liver histology of Asian patients with chronic hepatitis B on prolonged lamivudine therapy. Aliment Pharmacol Ther. Apr 1. 2005;21(7):841-9. [pmid: 15801919].
131 Yao GB. Management of hepatitis B in China. J Med Virol. Jul. 2000;61(3):392-7. [pmid: 10861652].
132 Liaw YF, Sung JJ, Chow WC, et al. Lamivudine for patients with chronic hepatitis B and advanced liver disease. N Engl J Med. Oct 7. 2004;351(15):1521-31. [pmid: 15470215].
133 Liaw YF, Leung NW, Chang TT, et al. Effects of extended lamivudine therapy in Asian patients with chronic hepatitis B. Asia Hepatitis Lamivudine Study Group. Gastroenterology. Jul. 2000;119(1):172-80. [pmid: 10889166].
134 Leung NW, Lai CL, Chang TT, et al. Extended lamivudine treatment in patients with chronic hepatitis B enhances hepatitis B e antigen seroconversion rates: results after 3 years of therapy. Hepatology. Jun. 2001;33(6):1527-32. [pmid: 11391543].
135 Dienstag JL, Goldin RD, Heathcote EJ, et al. Histological outcome during long-term lamivudine therapy. Gastroenterology. Jan. 2003;124(1):105-17. [pmid: 12512035].
136 Dienstag JL, Schiff ER, Wright TL, et al. Lamivudine as initial treatment for chronic hepatitis B in the United States. N Engl J Med. Oct 21. 1999;341(17):1256-63. [pmid: 10528035].
137 Honkoop P, de Man RA, Niesters HG, et al. Quantitative hepatitis B virus DNA assessment by the limiting-dilution polymerase chain reaction in chronic hepatitis B patients: evidence of continuing viral suppression with longer duration and higher dose of lamivudine therapy. J Viral Hepat. Sep. 1998;5(5):307-12. [pmid: 9795914].
138 Nevens F, Main J, Honkoop P, et al. Lamivudine therapy for chronic hepatitis B: a six-month randomized dose-ranging study. Gastroenterology. Oct. 1997;113(4):1258-63. [pmid: 9322520].
139 Chan HL, Wang H, Niu J, et al. Two-year lamivudine treatment for hepatitis B e antigen-negative chronic hepatitis B: a double-blind, placebo-controlled trial. Antivir Ther. 2007;12(3):345-53. [pmid: 17591024].
140 Yao G, Wang B, Cui Z, et al. A randomized double-blind placebo-controlled study of lamivudine in the treatment of patients with chronic hepatitis B virus infection. Chin Med J (Engl). May. 1999;112(5):387-91. [pmid: 11593504].
141 Kim YJ, Kim BG, Jung JO, et al. High rates of progressive hepatic functional deterioration whether lamivudine therapy is continued or discontinued after emergence of a lamivudine-resistant mutant: a prospective randomized controlled study. J Gastroenterol. Mar. 2006;41(3):240-9. [pmid: 16699858].
142 Tassopoulos NC, Volpes R, Pastore G, et al. Efficacy of lamivudine in patients with hepatitis B e antigen-negative/hepatitis B virus DNA-positive (precore mutant) chronic hepatitis B. Lamivudine Precore Mutant Study Group. Hepatology. Mar. 1999;29(3):889-96. [pmid: 10051494].
143 Lai CL, Gane E, Liaw YF, et al. Telbivudine versus lamivudine in patients with chronic hepatitis B. N Engl J Med. Dec 20. 2007;357(25):2576-88. [pmid: 18094378].
144 Hou J, Yin YK, Xu D, et al. Telbivudine versus lamivudine in Chinese patients with chronic hepatitis B: Results at 1 year of a randomized, double-blind trial. Hepatology. Feb. 2008;47(2):447-54. [pmid: 18080339].
145 Lai CL, Chien RN, Leung NW, et al. A one-year trial of lamivudine for chronic hepatitis B. Asia Hepatitis Lamivudine Study Group. N Engl J Med. Jul 9. 1998;339(2):61-8. [pmid: 9654535].
146 Mellerup MT, Krogsgaard K, Mathurin P, et al. Sequential combination of glucocorticosteroids and alfa interferon versus alfa interferon alone for HBeAg-positive chronic hepatitis B. Cochrane Database Syst Rev 2005; (3):CD000345.
147 Wu T, Roger H, Xie L, et al. Bicyclol for chronic hepatitis B. Cochrane Database Syst Rev 2006; (4):CD004480.
148 Higgins J, Green S. The Cochrane Collaboration. The Cochrane handbook for systematic reviews of interventions. John Wiley & Sons, Ltd. Cochrane Collaboration. Available at: http://www.cochrane.org/resources/handbook/handbook.pdf, 2006.
149 West S, King V, Carey TS, et al. Systems to rate the strength of scientific evidence. Evid Rep Technol Assess (Summ) 2002 Mar; (47):1–11.
150 Al-Marzouki S, Evans S, Marshall T, et al. Are these data real? Statistical methods for the detection of data fabrication in clinical trials. BMJ. Jul 30. 2005;331(7511):267-70. [pmid: 16052019].
151 Buyse M, George SL, Evans S, et al. The role of biostatistics in the prevention, detection and treatment of fraud in clinical trials. Statistics in Medicine. 1999;18(24):3435-51. [pmid: 10611617].
152 Dawson B, Trapp RG. Basic & Clinical Biostatistics (LANGE Basic Science). 3rd ed. New York: Lange Medical Books-McGraw-Hill; 2004.
153 Kahn HA, Sempos CT. Statistical Methods in Epidemiology (Monographs in Epidemiology and Biostatistics). USA: Oxford University Press; 1989.
154 Moher D, Cook DJ, Eastwood S, et al. Improving the quality of reports of meta-analyses of randomised controlled trials: the QUOROM statement. Quality of Reporting of Meta-analyses. Lancet. Nov 27. 1999;354(9193):1896-900. [pmid: 10584742].
155 Whitehead A. Meta-analysis of controlled clinical trials. Chichester, New York: John Wiley & Sons; 2002.
156 Atkins D, Briss PA, Eccles M, et al. Systems for grading the quality of evidence and the strength of recommendations II: pilot study of a new system. BMC Health Serv Res. Mar 23. 2005;5(1):25. [pmid: 15788089].
157 Atkins D, Eccles M, Flottorp S, et al. Systems for grading the quality of evidence and the strength of recommendations I: critical appraisal of existing approaches The GRADE Working Group. BMC Health Serv Res. Dec 22. 2004;4(1):38. [pmid: 15615589].
158 Aschengrau A, Seage GR. Essentials of Epidemiology in Public Health. Sudbury, Mass: Jones and Bartlett; 2003.
159 Vist GE, Hagen KB, Devereaux PJ, et al. Outcomes of patients who participate in randomised controlled trials compared to similar patients receiving similar interventions who do not participate. Cochrane Database Syst Rev 2007; (2):MR000009.
160 Egger M, Smith GD. Bias in location and selection of studies. BMJ. Jan 3. 1998;316(7124):61-6. [pmid: 9451274].
161 Dickersin K, Min YI. NIH clinical trials and publication bias. Online J Curr Clin Trials 1993 Apr 28; Doc No 50:[4967 words; 53 paragraphs].
162 Thornton A, Lee P. Publication bias in meta-analysis: its causes and consequences. J Clin Epidemiol. Feb. 2000;53(2):207-16. [pmid: 10729693].
163 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. Sep. 1986;7(3):177-88. [pmid: 3802833].
164 Viechtbauer W. Confidence intervals for the amount of heterogeneity in meta-analysis. Stat Med 2006 Feb 6.
165 Knapp G, Biggerstaff BJ, Hartung J. Assessing the amount of heterogeneity in random-effects meta-analysis. Biom J. Apr. 2006;48(2):271-85. [pmid: 16708778].
166 Egger M, Smith GD, Altman DG. Systematic Reviews in Health Care. London: NetLibrary, Inc. BMJ Books; 2001.
167 Ebrahim S. The use of numbers needed to treat derived from systematic reviews and meta-analysis. Caveats and pitfalls. Eval Health Prof. Jun. 2001;24(2):152-64. [pmid: 11523384].
168 Yang HZ, Zhao JA, Dai M, et al. Traditional Chinese medicine syndromes of chronic hepatitis B with precore mutant. World J Gastroenterol. Apr 7. 2005;11(13):2004-8. [pmid: 15800995].
169 van der Eijk AA, Niesters HG, Hansen BE, et al. Quantitative HBV DNA levels as an early predictor of nonresponse in chronic HBe-antigen positive hepatitis B patients treated with interferon-alpha. J Viral Hepat. Feb. 2006;13(2):96-103. [pmid: 16436127].
170 Papatheodoridis GV, Dimou E, Dimakopoulos K, et al. Outcome of hepatitis B e antigen-negative chronic hepatitis B on long-term nucleos(t)ide analog therapy starting with lamivudine. Hepatology. Jul. 2005;42(1):121-9. [pmid: 15962291].
171 Papatheodoridis GV, Petraki K, Cholongitas E, et al. Impact of interferon-alpha therapy on liver fibrosis progression in patients with HBeAg-negative chronic hepatitis B. J Viral Hepat. Mar. 2005;12(2):199-206. [pmid: 15720536].
172 Shindo M, Hamada K, Nishioji K, et al. The predictive value of liver fibrosis in determining the effectiveness of interferon and lamivudine therapies for chronic hepatitis B. J Gastroenterol. 2004;39(3):260-7. [pmid: 15065004].
173 Lampertico P, Del Ninno E, Vigano M, et al. Long-term suppression of hepatitis B e antigen-negative chronic hepatitis B by 24-month interferon therapy. Hepatology. Apr. 2003;37(4):756-63. [pmid: 12668967].
174 Brunetto MR, Oliveri F, Coco B, et al. Outcome of anti-HBe positive chronic hepatitis B in alpha-interferon treated and untreated patients: a long term cohort study. J Hepatol. Feb. 2002;36(2):263-70. [pmid: 11830339].
175 Di Marco V, Lo Iacono O, Camma C, et al. The long-term course of chronic hepatitis B. Hepatology. Jul. 1999;30(1):257-64. [pmid: 10385664].
176 Wong JB, Koff RS, Tine F, et al. Cost-effectiveness of interferon-alpha 2b treatment for hepatitis B e antigen-positive chronic hepatitis B. Ann Intern Med. May 1. 1995;122(9):664-75. [pmid: 7702228].
177 Poynard T, Zoulim F, Ratziu V, et al. Longitudinal assessment of histology surrogate markers (FibroTest-ActiTest) during lamivudine therapy in patients with chronic hepatitis B infection. Am J Gastroenterol. Sep. 2005;100(9):1970-80. [pmid: 16128941].
178 Hui CK, Leung N, Shek WH, et al. Changes in liver histology as a “surrogate” end point of antiviral therapy for chronic HBV can predict progression to liver complications. J Clin Gastroenterol. May–Jun. 2008;42(5):533-8. [pmid: 18344885].
179 Kim BK, Kim SA, Park YN, et al. Noninvasive models to predict liver cirrhosis in patients with chronic hepatitis B. Liver Int. Sep. 2007;27(7):969-76. [pmid: 17696936].
180 Lefkowitch JH. Liver biopsy assessment in chronic hepatitis. Arch Med Res. Aug. 2007;38(6):634-43. [pmid: 17613355].
181 Santantonio T, Niro GA, Sinisi E, et al. Lamivudine/interferon combination therapy in anti-HBe positive chronic hepatitis B patients: a controlled pilot study. J Hepatol. Jun. 2002;36(6):799-804. [pmid: 12044531].
182 Fleming TR, DeMets DL. Surrogate end points in clinical trials: are we being misled?. Ann Intern Med. Oct 1. 1996;125(7):605-13. [pmid: 8815760].
183 Hui CK, Leung N, Shek WH, et al. Changes in Liver Histology as a “Surrogate” End Point of Antiviral Therapy for Chronic HBV Can Predict Progression to Liver Complications. J Clin Gastroenterol. May/June. 2008;42(5):533-8. [pmid: 18344885].
184 Zhao H, Zhang YX, Chen XY, et al. [A clinical study of adefovir dipivoxil in treating lamivudine refractory HBeAg-positive chronic hepatitis B]. Zhonghua Nei Ke Za Zhi. Apr. 2007;46(4):294-7. [pmid: 17637268].
185 Yao GB, Zhu M, Wang YM, et al. [A double-blind, double-dummy, randomized, controlled study of entecavir versus lamivudine for treatment of chronic hepatitis B]. Zhonghua Nei Ke Za Zhi. Nov. 2006;45(11):891-5. [pmid: 17313873].
186 Yao GB, Zhang DF, Wang BE, et al. [A study of the dosage and efficacy of entecavir for treating hepatitis B virus]. Zhonghua Gan Zang Bing Za Zhi. Jul. 2005;13(7):484-7. [pmid: 16042878].
187 Zhao H, Si CW, Wei L, et al. [A multicenter, randomized, open-label study of the safety and effectiveness of pegylated interferon alpha 2b and interferon alpha 2b in treating HBeAg positive chronic hepatitis B patients]. Zhonghua Gan Zang Bing Za Zhi. May. 2006;14(5):323-6. [pmid: 16732903].
188 Liu G, Hu G, Tan D, et al. [A prospective investigation on interferon treatment of chronic hepatitis B]. Hunan Yi Ke Da Xue Xue Bao. 1998;23(4):400-2. [pmid: 11189407].
189 Zhu M, Xu B, Yao GB. [Durability of HBeAg seroconversion in lamivudine treatment of chronic hepatitis B patients]. Zhonghua Gan Zang Bing Za Zhi. Jul. 2005;13(7):534-6. [pmid: 16042894].
190 Song JW, Zhang G, Lin JG, et al. [Clinical study of lamivudine and interferon combinate administration to inhibit hepatitis B virus replication]. Zhonghua Gan Zang Bing Za Zhi. Oct. 2004;12(10):593-6. [pmid: 15504288].
191 Yao GB, Wang BE, Cui ZY, et al. [The long-term efficacy of lamivudine in chronic hepatitis B: interim analysis of 3-year's clinical course]. Zhonghua Nei Ke Za Zhi. Jun. 2003;42(6):382-7. [pmid: 12895320].
192 Ma H, You H, Yin S. [Clinical efficacy of lamivudine in the treatment of chronic hepatitis B]. Zhonghua Shi Yan He Lin Chuang Bing Du Xue Za Zhi. Jun. 2001;15(2):147-9. [pmid: 11436644].
193 Yao G, Wang B, Cui Z. [Long-term effect of lamivudine treatment in chronic hepatitis B virus infection]. Zhonghua Gan Zang Bing Za Zhi. Jun. 1999;7(2):80-3. [pmid: 10488413].
194 Lim SG, Krastev Z, Ng TM, et al. Randomized, double-blind study of emtricitabine (FTC) plus clevudine versus FTC alone in treatment of chronic hepatitis B. Antimicrob Agents Chemother. May. 2006;50(5):1642-8. [pmid: 16641430].
195 Lim SG, Ng TM, Kung N, et al. A double-blind placebo-controlled study of emtricitabine in chronic hepatitis B. Arch Intern Med. Jan 9. 2006;166(1):49-56. [pmid: 16401810].
196 Gish RG, Trinh H, Leung N, et al. Safety and antiviral activity of emtricitabine (FTC) for the treatment of chronic hepatitis B infection: a two-year study. J Hepatol. Jul. 2005;43(1):60-6. [pmid: 15922478].
197 Lee HS, Chung YH, Lee K, et al. A 12-week clevudine therapy showed potent and durable antiviral activity in HBeAg-positive chronic hepatitis B. Hepatology. May. 2006;43(5):982-8. [pmid: 16628625].
198 Yoo BC, Kim JH, Chung YH, et al. Twenty-four-week clevudine therapy showed potent and sustained antiviral activity in HBeAg-positive chronic hepatitis B. Hepatology. May. 2007;45(5):1172-8. [pmid: 17464992].
199 Yoo BC, Kim JH, Kim TH, et al. Clevudine is highly efficacious in hepatitis B e antigen-negative chronic hepatitis B with durable off-therapy viral suppression. Hepatology. Oct. 2007;46(4):1041-8. [pmid: 17647293].
200 Peters MG, Andersen J, Lynch P, et al. Randomized controlled study of tenofovir and adefovir in chronic hepatitis B virus and HIV infection: ACTG A5127. Hepatology. Nov. 2006;44(5):1110-6. [pmid: 17058225].
201 Dore GJ, Cooper DA, Pozniak AL, et al. Efficacy of tenofovir disoproxil fumarate in antiretroviral therapy-naive and -experienced patients coinfected with HIV-1 and hepatitis B virus. J Infect Dis. Apr 1. 2004;189(7):1185-92. [pmid: 15031786].