# Executive Summary

## Introduction

Hepatitis B is a highly prevalent disease with 350 million chronic cases worldwide^1^ and more than 4,000 incident cases in the United States in 2006.^2,^ ^3^ An estimated 2,000 to 4,000 deaths per year are related to Chronic Hepatitis B (CHB) liver diseases.^4,^ ^5^ The natural history of CHB is variable but generally indolent for many years to decades. Only 5 percent of acutely infected immunocompetent adults develop CHB. Demographic, clinical, and hepatitis B disease factors are believed associated with the development of CHB and poorer prognosis among those who develop CHB.

Treatment goals include prevention of cirrhosis, hepatocellular cancer, and liver failure. Suppressing replication of hepatitis B virus (HBV) is believed a key process to achieving this goal.^6^ Hepatitis B treatments include nucleos(t)ide analogues that suppress viral replication and interferons, naturally occurring cytokines with antiviral and immunomodulatory properties.^7,^ ^8^ Six agents used as monotherapy or in combination have been approved, as of June 2008, for use in the United States (standard interferon alfa-2b, peginterferon alfa-2a, lamivudine, telbivudine, adefovir, and entecavir). A seventh, tenovir, was approved in August 2008. Two basic therapeutic approaches exist. A defined self-limited course (e.g., 4–12 months) followed by monitoring off treatment is generally used with interferon-based therapy. Long-term continuous suppressive therapy is used for other direct antiviral agents. Researchers have proposed clinical outcomes and biochemical, virologic, and histologic measures to determine an individual's risk for disease progression, identify candidates for treatment, and assess treatment effectiveness and harms.^1,^ ^9,^ ^10^

Demographic and virologic diversity within HBV infected populations and within individuals over extended periods of time, including different genotypes of HBV and developing viral mutations, make it difficult to predict individualized outcomes from population-based studies and in patients with antiviral drug resistance.^11^ Furthermore, much of the literature provides incomplete detail to characterize risk factors for progression.

The Minnesota Evidence-based Practice Center (EPC) conducted a systematic review to address the following questions for a National Institutes of Health (NIH) Consensus Conference related to Management of Chronic Hepatitis B in Adults.

### Key Questions

Consensus conference question 1. What is the natural history of Hepatitis B?

EPC question 1. What is the evidence that the following population characteristics or clinical features associated with hepatitis B are predictive of hepatocellular carcinoma, liver failure, cirrhosis, liver-related death, and all-cause mortality?

Consensus conference question 2. What are the benefits and risks of the current therapeutic options for hepatitis B with defined or continuous courses of treatment?

EPC question 2a. What is the efficacy (or effectiveness) of interferon therapy, oral therapy, and various combinations in treating hepatitis B with defined or continuous courses of treatment?

EPC question 2b. What are the known harms of interferon therapy, oral therapy, and various combinations in treating hepatitis B with defined or continuous courses of treatment?

Surrogate outcomes of interest. Alanine aminotransferase (ALT) and/or aspartate aminotransferase (AST) levels, HBV viral load, change in Hepatitis B e antigen (HBeAg) status, hepatitis B surface antigen (HBsAg) conversion, liver biopsy findings (necroinflammatory activity or stage of fibrosis), and drug resistance.

Clinical outcomes of interest include hepatocellular carcinoma, liver failure, cirrhosis, liver-related death, all-cause mortality.

Consensus conference question 3. Which persons with hepatitis B should be treated?

EPC question 3a. Are there differences in efficacy/effectiveness of treatments for treatment naïve versus drug-resistant patients, chronic HBeAg-positive versus HBeAg-negative patients, or for other subpopulations (as defined previously)?

EPC question 3b. Is there evidence that specific subpopulations do not require treatment for hepatitis B (i.e., that the surrogate and/or clinical outcomes are equivalent or superior when not exposed to treatment?)

Consensus conference question 4. What measures are appropriate to monitor therapy and assess outcomes?

EPC question 4. What is the evidence that changes in surrogate endpoints in response to treatment are reliable predictors of long-term resolution or slowed progression of disease? Patient Population: Adults (≥ 18 years of age), including elderly and members of racial/ethnic minority populations.

## Methods

We searched MEDLINE^®^, the Cochrane library,^12^ Medwatch,^13^ United Kingdom Current Problems in Pharmacovigilance,^14^ and the European Public Assessment Report^15^ to find original studies of adults with CHB published in English that reported clinical and intermediary outcomes^16^ for observational studies and randomized controlled trials (RCTs) of antiviral drug therapies approved by the Food and Drug Administration (FDA) for CHB.^17^

For question 1, we included studies if they reported clinical outcomes, had at least 1 year of followup between the measurement of predictive factors, had at least one of the outcomes of interest, and reported results for a CHB only population. All studies meeting these criteria were included if the study reported results from a U.S. population. Only studies of at least 1,000 participants outside of the United States were included. For questions 2–4, RCTs of drugs approved by the FDA for CHB^17^ were eligible. We included pegylated interferon alfa-2b that has been intensively examined in patients with CHB^18^ but not yet approved in the United States. We included observational studies of more than 50 treated adults with more than 1 year followup that examined surrogate predictors of clinical outcomes for question 4. We prioritized clinical outcomes and criteria of complete and sustained response for intermediate virological, biochemical, and histological outcomes.

We excluded studies evaluating children and adolescents, pregnant women, adults with hepatocellular carcinoma, patients undergoing transplantation or treatment for malignancies, and trials of reverse transcriptase inhibitor that included fewer than 50 patients or examined treatments for less than 24 weeks. We assessed level and confidence (low, medium, or high) of evidence using a subset of the U.S. Preventive Services Task Force criteria.

We determined low levels of evidence and confidence when data were from small RCTs, from RCTs or observational studies with serious flaws in design/analysis, and from post hoc subgroup analysis; moderate levels when large multinational RCTs or observational studies or several RCTs reported consistent associations or effect of the same drugs; and high levels from multiple high quality RCTs or observational studies in applicable patients reporting consistent sustained (off therapy at least 6 months) effects. We synthesized the results calculating relative risk and absolute risk difference (ARD) at 95 percent confidence levels and used meta-analyses to assess the consistency of the association between treatments and outcomes with random effects models.^9^ ^10^

## Results

### EPC Question 1. What is the evidence that the following population characteristics or clinical features associated with hepatitis B are predictive of hepatocellular carcinoma, liver failure, cirrhosis, liver-related death, and all-cause mortality?

Forty-one articles met inclusion criteria,^19^–^59^ including 14 publications representing eight unique populations within the United States.

Chronic carriers of HBsAg had substantially higher rates of hepatocellular carcinoma, cirrhosis, and death than people who have never been chronically HBsAg-positive.^21^ ^24^ ^30^ ^39^ ^45^ The annual incidence of hepatocellular carcinoma (HCC) was only 0.1 percent in asymptomatic HBsAg individuals, 1 percent in patients with CHB, but increased to 3–10 percent in patients with cirrhosis.^60^ Patients with CHB developed cirrhosis at a rate of 2 percent per year. Reports have shown large differences in clinical event rates across diagnostic groups such as inactive HBsAg carriers, CHB without cirrhosis, and CHB with cirrhosis. A U.S. cohort study followed 400 HBsAg patients (70 percent born in Asia) for over 7 years.^47^ Among 110 inactive carriers, none developed HCC or died of a liver-related disease, and only one died of any cause. Among patients with CHB but no cirrhosis, 6 percent developed HCC and died from it, while another 2 percent died from nonliver related causes. Among those with CHB and cirrhosis, 16 percent were diagnosed with HCC and 42 percent died during followup (all from liver-related causes).

Increased age was generally associated with small to moderately increased clinical outcomes; however, the evidence was inconclusive regarding whether the association between age and clinical outcomes is explained by duration of infection, age of infection, comorbidities in older individuals, and other factors that might be different between older and younger patients. Likewise, there was inconclusive evidence that geographic location or race/ethnicity contribute meaningfully for the prediction of clinical outcomes. There was high confidence that males have greater than twofold increased rates of clinical outcomes compared to women. A positive family history of HCC was associated with an increased risk of HCC, but the extent this was independent of age of infection and duration of disease is unclear. Estimates regarding coinfection and clinical outcomes could only be made with low confidence due to the paucity or inconsistency of the data; coinfection with either human immunodeficiency virus (HIV) or hepatitis delta virus (HDV) appeared associated with strongly increased liver-related mortality, and coinfection with hepatitis C virus (HCV) appeared associated with moderately increased HCC risk. Cirrhosis is a strong predictor of HCC and death. There was little to no evidence regarding the impact of nonalcoholic liver disease or alcohol consumption on future development of cirrhosis, HCC, or death.

Increased HBV deoxyribonucleic acid (DNA) viral load was strongly associated with increased HCC and liver-related mortality after accounting for baseline cirrhosis, HBeAg status, and ALT levels. There was no evidence regarding whether reduction in HBV DNA viral load was associated with better outcomes. HBV genotypes may be associated with differing risk of clinical outcomes. HBsAg loss was associated with a reduction in risk of cirrhosis, but data were sparse. There was no evidence as to whether HBsAg loss was associated with other improved outcomes. HBeAg-positive status was associated with poorer outcomes independent of other disease factors. Reversion or multiple switches in HBeAg status was associated with increased HCC; however, the mechanism of this is unclear. Basal core promoter mutations (T1762/A1764) and the precore (PC) mutation (A1896) were associated with increased HCC and basal core promoter mutations may be associated with small increases in liver-related death rates. ALT was modestly associated with associated with increased risk of HCC and cirrhosis after accounting for baseline cirrhosis, HBeAg status and HBV viral load.

### Questions 2 and 3

Ninety-three articles represented 60 unique randomized trials of interferon alfa-2b,^61^–^92^ peginterferon alfa-2a,^93^–^97^ peginterferon alfa-2b,^98^–^109^ adefovir,^10,^ ^110^–^120^ entecavir,^121^–^126^ lamivudine,^64,^ ^67,^ ^95,^ ^96,^ ^119,^ ^127^–^142^ or telbivudine.^109,^ ^120,^ ^127,^ ^143^ Treatment duration averaged 44±22 weeks and followup post-treatment 98±158. Most enrollees were Asian (64 percent) or white (30 percent) ethnicity/race. ^61^ ^63,^ ^66,^ ^69^ ^81,^ ^83,^ ^84,^ ^86,^ ^87,^ ^90,^

Sixteen articles reporting on mortality, HCC, hepatic decompensation, or cirrhosis were not of sufficient size or duration to adequately assess the effect of treatments on these outcomes.^70,^ ^83,^ ^85,^ ^86,^ ^90,^ ^91,^ ^96,^ ^106,^ ^111,^ ^121,^ ^122,^ ^124^–^126,^ ^132,^ ^141^ Most studies reported on serologic, virologic, or histologic outcomes with marked variation in patients enrolled, dose or duration of interventions and comparators, time to evaluate outcomes at the end of or at followup off therapies, and definitions of outcomes. When treatment effects were noted, they were rarely reassessed or reported in similar patient populations, and/or drug combinations, doses, or durations. No study assessed outcomes according to the multiple patient and disease characteristics frequently used to determine treatment strategies (e.g., according to HBeAg plus HBV DNA plus ALT plus cirrhosis status). There was a low level of evidence from individual studies or inconsistent results from several studies for most outcomes.

### Question 2a. What is the efficacy (or effectiveness) of interferon therapy, oral therapy, and various combinations in treating hepatitis B with defined or continuous courses of treatment?

#### Clinical outcomes

Mortality. Antiviral medications did not reduce mortality versus placebo, other antiviral medications, or in combination with corticosteroids, regardless of baseline HBeAg or cirrhosis status in 14 RCTs that were not designed to test long-term clinical outcomes.^70,^ ^83,^ ^86,^ ^90,^ ^96,^ ^106,^ ^111,^ ^121,^ ^122,^ ^124^–^126,^ ^132^

Cirrhosis. A small trial failed to demonstrate that interferon alfa-2b prevented cirrhosis in HBeAg-positive patients.^83^ Another small RCT found no significant difference in histologically confirmed cirrhosis after interferon alfa-2b alone or with simultaneous prednisone.^85^ No data were available from RCTs for other antiviral drugs or longer followup.

Hepatic decompensation was not prevented by lamivudine compared to placebo^141^ or entecavir compared to lamivudine^122,^ ^126^ in three underpowered trials.^122,^ ^126,^ ^141^

Hepatocellular carcinoma was not prevented in four studies with inadequate size and duration.^85,^ ^91,^ ^111,^ ^132^ In one RCT, analysis that adjusted for country, sex, baseline ALT level, Child-Pugh score, and Ishak fibrosis score and excluded five individuals who developed HCC within the first year of the study found a borderline significant effect of lamivudine.^132^ This study noted a nonsignificant increase in all cause mortality.

#### Intermediate outcomes

Evidence suggested drug effects on viral load or replication, liver enzymes, and histology at end-of-treatment and lasting from at least <3 to >6 months off treatment. No one treatment improved all examined outcomes and few assessed complete response or sustained outcomes (i.e., at >6 months off treatment).

HBV DNA clearance was assessed using assays with different sensitivities to detect HBV DNA. Adefovir^10,^ ^110,^ ^112,^ ^113^ and lamivudine ^67,^ ^127,^ ^129,^ ^131,^ ^133,^ ^136,^ ^139^ increased HBV DNA clearance at end of treatment versus placebo. Entecavir increased clearance versus lamivudine^121,^ ^122,^ ^123,^ ^126^ with inconsistent effect size. Lamivudine was less effective than adefovir in lamivudine-resistant patients^119^ and less effective than telbivudine in HBeAg-positive patients.^127^ Limited evidence suggested that HBV DNA clearance was maintained at followup off therapy ranging from 18–24 weeks after interferon alfa-2b,^69,^ ^87^ lamivudine,^139^ or adefovir administration.^10^

HBeAg loss was assessed in 35 trials. ^61,^ ^62,^ ^64,^ ^66,^ ^67,^ ^69,^ ^72,^ ^75,^ ^80,^ ^83,^ ^86^–^88,^ ^92,^ ^94,^ ^96,^ ^98,^ ^99,^ ^102,^ ^106,^ ^109,^ ^112,^ ^113,^ ^117,^ ^119,^ ^120,^ ^122^–^125,^ ^127,^ ^136,^ ^140,^ ^143,^ ^144^ HBeAg clearance off treatment was demonstrated for interferon alfa-2b.^64,^ ^83,^ ^87^ Lamivudine for 52 weeks versus placebo increased HBeAg loss at 16 weeks off therapy.^67,^ ^136^ HBeAg loss at 24 weeks post treatment was greater after peginterferon alfa-2a versus lamivudine.^94,^ ^96^

HBeAg seroconversion was assessed in 36 studies.^10,^ ^62^–^64,^ ^66^–^68,^ ^75,^ ^80,^ ^83,^ ^88,^ ^91,^ ^94,^ ^96,^ ^99,^ ^106,^ ^109,^ ^111^–^113,^ ^117,^ ^119,^ ^120,^ ^122^–^127,^ ^133,^ ^136,^ ^140,^ ^141,^ ^143^–^145^ Lamivudine^64,^ ^67,^ ^127,^ ^136,^ ^140,^ ^141^ or adefovir increased HBeAg seroconversion versus placebo.^112,^ ^113^ Interferon alfa-2b^64,^ ^83^ increased post-treatment seroconversion. Lamivudine monotherapy failed to sustain seroconversion.^67,^ ^136^ Interferon alfa-2b plus lamivudine demonstrated inconsistent effects on seroconversion at 6–28 weeks of followup^64,^ ^67^ with significant benefit in a pooled analysis from four RCTs using individual patient data.^64^ Telbivudine versus adefovir^120^ or peginterferon alfa-2a versus lamivudine increased post treatment HBeAg seroconversion.^96^ Peginterferon alfa-2a plus lamivudine increased HBeAg seroconversion versus lamivudine alone but not versus peginterferon alfa-2a alone.^96^

HBsAg clearance. Nine studies compared active drugs with placebo or no treatment.^10,^ ^67,^ ^70,^ ^83,^ ^84,^ ^91^ Only one RCT of HBeAg-positive patients found a significant increase in HBsAg loss after interferon alfa-2b.^84^ Steroid pretreatment followed by interferon alfa-2b versus no antiviral drugs increased HBsAg loss at the end of treatments.^70,^ ^84^ Active treatments compared to each other did not demonstrate differences post-treatment HBsAg loss or combined outcomes that included loss HBsAg clearance.^61,^ ^63,^ ^66,^ ^67,^ ^69,^ ^71,^ ^73,^ ^74,^ ^76,^ ^80,^ ^82^–^85,^ ^87^–^91,^ ^98,^ ^99,^ ^109,^ ^111,^ ^119,^ ^122,^ ^126,^ ^136,^ ^139^

ALT normalization was greater after adefovir versus placebo.^10,^ ^113^ Lamivudine increased rates of ALT normalization versus placebo at 24 weeks off treatment in HBeAg-negative patients.^139^ Interferon Alfa-2b at doses 35 million units (MU)/week compared to no antiviral treatment increased rates of ALT normalization at 8–24 weeks of followup. ^84^ ^87^ Sustained ALT normalization at 24 weeks off treatment was greater after peginterferon alfa-2a compared to lamivudine^95,^ ^96^ and after combined therapy of peginterferon alfa-2a with lamivudine compared to lamivudine alone.^95,^ ^96^

Histological improvement off treatment in necroinflammatory scores was reported in only one RCT^95^ after peginterferon alfa-2a compared to lamivudine in HBeAg-negative patients.^95^

Combined virologic and biochemical outcomes. Low to moderate evidence suggested that some examined drugs or their combinations improved combined virologic and biochemical outcomes immediately after^75,^ ^81,^ ^84,^ ^91,^ ^122,^ ^126,^ ^127,^ ^139^ and post treatment.^61,^ ^73,^ ^75,^ ^81,^ ^82,^ ^85,^ ^87,^ ^89,^ ^91,^ ^106,^ ^122,^ ^125,^ ^139^

### Question 2b. What are the known harms of interferon therapy, oral therapy, and various combinations in treating hepatitis B with defined or continuous courses of treatment?

Nucleos(t)ide analogues were well tolerated during the duration studied with safety profiles and withdrawal comparable to placebo. Adverse events were usually mild, including fatigue, headache, abdominal pain, nausea, and diarrhea. Pegylated interferon therapy, alone or combined with lamivudine, was not as well tolerated as lamivudine monotherapy. Subjects treated with combined or monotherapy were more likely to withdraw from a study or require dose modification due to an adverse event compared to lamivudine. Adverse events associated with pegylated interferon include flu-like illness, hair loss, anorexia, and less commonly depression. Pegylated interferon and conventional interferon therapy had comparable safety profiles.

Similar incidences of Grade 3 or 4 laboratory abnormalities were observed for adefovir and placebo with the exception of increases in ALT and AST levels. Subjects with or at risk of impaired renal function may develop nephrotoxicity with adefovir. Twenty-five percent of lamivudine subjects had an ALT level at least three times the baseline level compared to 8 percent of placebo subjects during the post-treatment period. One trial noted greater incidences in Grade 1–4 creatine kinase (CK) elevations with telbivudine compared to lamivudine. Higher frequencies of Grade 3–4 elevations in ALT and AST occurred with lamivudine compared to telbivudine. ALT flares occurred in 24 percent and 9 percent of the lamivudine and entecavir groups, respectively. Laboratory abnormalities were higher in the peginterferon alfa-2a monotherapy and combined therapy groups compared to lamivudine. Overall, dose modification, due mainly to laboratory abnormalities, was required for 46 and 47 percent of peginterferon mono and combined therapy recipients, respectively. Neutropenia and thrombocytopenia were cited as the most common abnormalities.

### Question 3a. Are there differences in efficacy/effectiveness of treatments for treatment naïve versus drug-resistant patients, HBeAg-positive versus HBeAg-negative patients, or for other subpopulations (as defined previously)?

Potential modifiers of treatment effectiveness and harm include patient, disease, viral, biochemical and therapeutic factors. Fifteen studies examined treatment effects among patient subpopulations immediately^61,^ ^64,^ ^75,^ ^93,^ ^105,^ ^107,^ ^124,^ ^127,^ ^130,^ ^132,^ ^133,^ ^135,^ ^140,^ ^141,^ ^143^ and at followup off active drugs (n=23 studies).^61^–^65,^ ^72,^ ^73,^ ^75,^ ^84,^ ^85,^ ^90,^ ^93,^ ^96,^ ^97,^ ^99,^ ^100,^ ^102,^ ^104,^ ^106,^ ^108,^ ^109,^ ^114,^ ^126^ No RCTs directly compared patients with eAg+ versus eAg-, treatment naive versus prior treated, or drug resistant with baseline cirrhosis versus no-cirrhosis. Results from studies enrolling relatively pure populations indicate that there is inconsistent data that baseline treatment status, eAg status, or cirrhosis influence histological, virological, or biochemical end points.

Younger patient age was associated with enhanced HBV DNA clearance and ALT normalization in patients treated with pegylated interferon versus lamivudine.^93,^ ^109^

Baseline body weight was not associated with HBV DNA clearance and ALT normalization.^93^

Disease progression or treatment induced sustained ALT normalization and HBV DNA clearance did not vary by gender (five studies, three antiviral agents used as monotherapy).^72,^ ^93,^ ^109,^ ^132,^ ^141^

Patients with longer duration of hepatitis responded to therapy 2.5 times less frequently compared to those with shorter duration of the disease. Sustained virologic response at 48 weeks off therapy (HBeAg and HBV DNA loss) to interferon alfa-2b combined with lamivudine was greater in those with an estimated duration of hepatitis of 10 years or less after adjustment for patient gender and age.^63^

Treatment induced followup histology, HBeAg loss or DNA clearance and ALT normalization did not clearly vary by baseline histology severity.^63,^ ^64,^ ^97,^ ^127^ HBeAg loss was higher per unit increase in baseline histological activity index (HAI) score.^64^ Lamivudine improved histology compared to placebo among patients with moderate or severe hepatitis but failed in those with mild hepatitis.^145^ Interferon alfa-2b increased post-treatment HBeAg loss compared to placebo among patients with pretreatment HAI score 5–9 but not in patients with pretreatment HAI score 0–4 or >10.^64^ Interferon alfa-2b combined with lamivudine compared to placebo increased post-treatment HBeAg clearance in patients with pretreatment HAI score 5–9 with no significant effects in those with pretreatment HAI score 0–4 or >10.^64^ Off treatment virologic response to interferon alfa-2b plus lamivudine increased in those with a baseline inflammation score of seven or more, independent of gender and age.^63^ Presence of steatosis did not modify the effect of peginterferon alfa-2a combined with lamivudine on post-treatment response defined as HBV DNA disappearance and ALT normalization in both HBeAg-positive and negative patients.^97^ Adjusted rates of post-treatment response were greater per increase in baseline Knodell HAI.^97^

It was difficult to draw conclusions on the effect of viral load on outcomes off therapy due to varying assays and cut offs of baseline DNA. There were inconsistent effects with no dose-response relationship observed. Compared to placebo, lamivudine reduced disease progression regardless of baseline viral load. Compared to lamivudine, peginterferon plus lamivudine was more effective for combined end points regardless of baseline viral load. No studies reported subgroups with very low viral load. Treatment induced HBeAg loss, ALT normalization, or histology improvement varied with baseline viral load. At followup post treatment, interferon alfa-2b increased loss of HBV DNA and HBeAg among patients with baseline HBV DNA 2-99 pg/ml but failed among those with higher baseline HBV DNA.^84^ There was not a significant HBV DNA unit dose-response versus no treatment.^61^ Interferon alfa-2b increased off treatment rates of HBeAg loss among patients with baseline HBV DNA <10pg/ml but not in those with higher viral loads.^61^ Interferon alfa-2b with steroid pretreatment increased post-treatment treatment rates of HBV and HBeAg loss among patients with baseline HBV DNA 2-99 pg/ml but failed in those with HBV DNA >100 pg/ml.^84^ Combined administration of interferon alfa-2b with lamivudine resulted in greater off treatment HBV DNA clearance and HBeAg seroconversion in patients with baseline HBV DNA >10^7^ copies/mL.^75^ Peginterferon alfa 2-a provided greater sustained response compared to lamivudine in patients with baseline HBV DNA range in the 25–75 percentile^93,^ ^96^ with random differences at other percentiles.

Low quality evidence indicates that treatment effects may vary by baseline HBeAg status.^124,^ ^132,^ ^143^ Lamivudine versus placebo decreased overall disease progression among HBeAg-positive^132^ but failed in HBeAg-negative patients.^132^ Telbivudine versus lamivudine improved outcomes among HBeAg-positive with random differences in HBeAg-negative patients.^109,^ ^143^ Patients who were HBeAg-negative at baseline experienced improvement in biochemical, virological, and histological outcomes after adefovir therapy and pegylated interferon alfa 2-a monotherapy or combination with lamivudine.^10,^ ^71,^ ^74,^ ^76,^ ^79,^ ^81,^ ^91,^ ^93,^ ^95,^ ^110,^ ^111^ Adefovir^10,^ ^110^ and pegylated interferon alfa 2-a with lamivudine^95^ improved off-treatment viral clearance in HBeAg-negative patients.

Treatment induced ALT normalization and HBV DNA clearance or HBeAg seroconversion varied by HBV DNA genotype. There was better response among patients with genotype B and C at the end of treatments^93^ and at followup off therapies.^65,^ ^93,^ ^96,^ ^99,^ ^100,^ ^108,^ ^109^ Patients with genotype A had lower adjusted odds of response compared to patients with genotype C.^93^ Off treatment response to the same treatments also differed with greater adjusted odds of success among patients with genotype B versus D and with genotype C versus D.^93^

Baseline ALT levels. Treatment induced HBeAg clearance and seroconversion, HBeAg loss or virologic clearance varied by baseline ALT levels with inconsistent evidence of better response among patients with elevated baseline ALT (ten studies; three medications used as mono or combination therapy).

HBeAg seroconversion after peginterferon alfa-2a alone or in combination with lamivudine was higher versus lamivudine alone among patients naïve to lamivudine,^96^ with no significant differences among patients previously treated with lamivudine. Five RCTs enrolled lamivudine resistant patients.^118,^ ^119,^ ^124,^ ^125,^ ^141^ Adefovir plus lamivudine versus lamivudine increased ALT normalization and HBV DNA clearance but not HBeAg clearance or seroconversion in lamivudine-resistant patients^119^ without improvement in outcomes compared to adefovir monotherapy.^119^ Entecavir increased HBV DNA and HBeAg clearance and normalization of ALT in lamivudine-refractory HBeAg-positive patients compared to lamivudine^125,^ ^124^ and improved necroinflammatory Knodell scores and Ishak fibrosis scores in lamivudine resistant patients.^125^ Patients who failed previous interferon therapy did not benefit from adding lamivudine.^92^

### Question 3b. Is there evidence that specific subpopulations do not require treatment for hepatitis B (i.e., that the surrogate and/or clinical outcomes are equivalent or superior when not exposed to treatment?)

Studies did not demonstrate improvement in clinical outcomes. However, RCTs were not adequately designed to accurately assess clinical outcomes. Evidence in key question 1 demonstrates that the clinical course of CHB is asymptomatic and indolent in most adults. Therefore, the majority would be unlikely to benefit from treatment for many years. Treatment to reduce viral transmissibility is of potential immediate and long-term public health benefit. Patient, disease, and comorbidity factors are of limited value in assessing prognosis in order to make treatment decisions in an individual patient. A key exception is the presence of cirrhosis where there was high confidence that this led to a large increased risk of poor clinical outcomes. Therefore, clinicians may decide to initiate therapy in these individuals because of a poor natural history.

Specific subpopulations would not require treatment if their clinical outcomes (and possibly validly defined surrogate measures) were equivalent or superior to similar populations not receiving treatment or if harms of therapy outweighed benefits. The effects of eligible drugs on asymptomatic carriers have not been published in RCTs. Monotherapy with interferon alfa-2b or lamivudine and a combination of interferon alfa-2b with steroids failed to sustain virologic response in patients with CHB. Individuals who failed previous interferon alfa-2b therapy did not benefit after combined interferon and lamivudine treatment. Patients with HBeAg did not experience greater off treatment HBeAg seroconversion after interferon alfa-2b combined with lamivudine. Interferon alfa-2b did not improve histology or increase rates of resolved hepatitis.^82^–^84,^ ^89,^ ^91^ Interferon alfa-2b combined with lamivudine compared to placebo failed to increase HBeAg clearance or sustained HBeAg seroconversion in patients treated with lamivudine^64^ and in nonresponders to the previous interferon therapy.^67^ Lamivudine compared to placebo failed to sustain HBeAg seroconversion in interferon nonresponders^67^ and in treatment naïve patients.^136^ Lamivudine did not sustain HBsAg loss, HBV DNA clearance, or ALT normalization.^67,^ ^136,^ ^139^

We assessed whether certain patient or hepatitis characteristics were associated with risk of serious adverse events or noncompliance that might lead to a decision not to initiate treatment. Few data were available. Several adverse effects were specific for patients with different HBeAg baseline status. Only HBeAg-negative patients experienced dose modification due to neutropenia or thrombocytopenia.^95^ Combined therapy did not prevent worsening of fibrosis scores in HBeAg-negative patients.^95^ In HBeAg-positive patients depression, diarrhea, dizziness, nausea, pruritus, rash, or rigors were more common after combined therapy with lamivudine compared to lamivudine alone.^96^ YMDD mutations were more common in HBeAg-positive patients after combined therapy compared to peginterferon alfa-2a alone.^96^ Pyrexia was more prevalent after peginterferon alfa-2a compared to lamivudine.^95,^ ^96^ Only HBeAg-positive at baseline patients experienced ≥ 1 serious adverse event,^96^ while only HBeAg-negative patients needed dose modification due to neutropenia or thrombocytopenia.^95^ The rates of YMDD mutations were lower after interferon compared to lamivudine in patients with HBeAg-positive CHB.^96^

### Question 4: What is the evidence that changes in surrogate endpoints in response to treatment are reliable predictors of long-term resolution or slowed progression of disease?

Studies were not adequately designed to assess the effectiveness of treatments on clinical outcomes, a necessary prerequisite for determining surrogates. Treatments did not improve all-cause mortality, liver-related death, hepatic carcinoma, or hepatic decompensation. We found even fewer studies that assessed the association of baseline ‘surrogates’ with clinical outcomes. We did not find any RCTs that evaluated whether change in a clinical outcome was explained by a treatment related change in a potential surrogate. We found associations of intermediate markers with clinical outcomes and advise caution against calling them surrogates. Four included studies were either long-term followup of prior RCTs, with randomization no longer preserved, or cohort studies of once-treated patients, where surrogate markers were assessed in relation to long-term clinical outcomes. There was lack of uniformity in surrogate and endpoint measurement, timing of measurement, definitions, and measurement of effect controlling for relevant effect. We have low confidence whether any of the listed biochemical, histologic, or virologic measures are adequate surrogate markers. Patients who are positive for HBsAg are considered to be capable of transmitting hepatitis B virus to uninfected individuals. Clearance of HBsAg, HBV DNA, or HBeAg seroconversion could be considered an appropriate clinical outcome from the perspective of transmission prevention and public health rather than or in addition to possibly being a surrogate for clinical outcomes in infected patients.

There is limited information on the association of potential surrogates of ALT normalization, detectable HBV DNA, worsening histology, and change in HBeAg on the composite endpoint of decompensation, cirrhosis and HCC, and all-cause mortality among patients treated with peginterferon alpha-2a plus lamivudine, interferon alpha-2a or 2b, or lamivudine. Among HBeAg-positive patients treated with interferon alpha-2a or 2b, a 2-point increase in HAI score at the end of treatment may be a potential surrogate for liver complications. Among HBeAg-positive patients treated with lamivudine alone or in combination with peginterferon interferon alpha-2a, HBeAg seroconversion may be an incomplete surrogate for decompensation. There are no available data that assess HBsAg seroconversion among treated patients on clinical outcomes. There are no data that assess drug resistance among treated patients or following treatment with adefovir or telbuvidine on clinical outcomes.

## Discussion

Predicting CHB natural history and accurately evaluating the effectiveness of treatments is difficult, in part due to the long-term and heterogeneous nature of the disease. There is little high quality information with which to make accurate prognostic and treatment decisions. Limited evidence from observational studies suggested that increased age and duration of infection, male gender, coinfection with HIV, HCV, or HDV, increased HBV DNA viral load, and cirrhosis were associated with increased risk of death and cancer. RCTs were not designed to detect effects of drugs on clinical outcomes. Only one trial reported significant protective effect. The beneficial effect of lamivudine on HCC occurred only after secondary adjusted analyses and exclusion of five individuals who developed hepatocellular cancer within the first year of the study.^132^ This study also reported a nonsignificant increase in all-cause mortality with lamivudine. Treatment goals proposed by present guidelines include intermediate outcomes (HBV DNA and HBeAg loss, ALT normalization, improvement in histology) with very limited evidence that such measures are associated with significant prevention of liver failure or cancer. Ongoing clinical trials registered in www.clinicatrials.gov defined intermediate measures as primary outcomes with no expected increase in the rates of resolved hepatitis or prevention of cirrhosis, liver failure, or HCC. Low to moderate levels of evidence suggested that improvements off treatment (<3 months to >6 months) in intermediate outcomes occurred after mid-duration treatment. The majority of treatments demonstrated marginal or random effects for off treatment HBsAg seroconversion combined with other criteria of complete response or resolved hepatitis B. Consistent pooled risk reductions from multiple studies were observed for the following: interferon alfa-2b (HBeAg loss and HBV DNA loss); adefovir (ALT normalization and HBV DNA loss); and lamivudine (HBeAg seroconversion, HBV DNA loss, improved necroinflammatory scores, ALT normalization). Biological markers to monitor the effects of drug therapies have not been evaluated in RCTs.

Very limited low level evidence was available for patient subpopulations. Few large working groups conducted appropriate analyses controlling for possible confounding factors, however, consistency in the effects was not possible to estimate considering large variability in patient characteristics, examined treatments, and different definitions of the outcomes. Published evidence of different treatment effects in aged, males, and patients with longer duration of hepatitis, large viral load, and viral genotype B should generate hypotheses for future research rather that result in valid individualized predictions of treatment benefits.

Deciding which patients should not receive treatment is difficult and necessarily made between patient and health care provider. Evidence does not indicate that therapies improve clinical outcomes but does not exclude potential effect. Furthermore, there was very limited evidence indicating which patients should or should not be treated. No RCTs evaluated treatments among carriers without chronic hepatitis. Limited evidence suggested small treatment benefits in HBeAg-negative patients with the same probability of harms independent of baseline HBeAg status. Patients with active CHB experienced off treatment benefits on selected intermediate outcomes after interferon alfa-2b, adefovir, lamivudine, or pegylated interferon alfa-2a. Absolute rates were low and indirect comparisons of absolute rates not valid.

Nucleos(t)ide analogues adefovir and lamivudine were well tolerated and adverse events were generally mild during the duration studied. Safety profiles were comparable to placebo, with the exception of significant increases in ALT and AST levels due to adevovir and increased resistance and mutation with lamivudine. Subjects with or at risk of impaired renal function may develop nephrotoxicity with chronic administration of adefovir. Pegylated interferon, alone or combined with lamivudine, was not as well tolerated as lamivudine monotherapy. A flu-like illness is commonly associated with peginterferon alfa-2a treatment. Pegylated interferon and conventional interferon therapy had comparable safety profiles. Dose modification was common.

## Gaps in Evidence and Recommendations for Future Research

The greatest knowledge gap derives from the lack of large, long-term randomized trials demonstrating that interventions with antiviral agents improve all-cause mortality, liver-related mortality, hepatocellular carcinoma, and/or hepatic decompensation. Additional valid clinical outcomes could include quality of life and hospitalizations. Randomized trials did not reliably demonstrate long-term reduction in infectivity. Accurate assessments of effectiveness or decisions on whom to treat are not possible. Because individuals with baseline cirrhosis are at greatest risk for poor outcomes, they stand the most to benefit from effective therapies. Assessment of baseline and followup patient, biochemical, virological, and histological measures can then be utilized to determine if they are valid surrogates of treatment effectiveness in the studied patients. If randomized trials are judged not feasible, then accurate collection of valid epidemiologic data in clinical settings or in registry studies might be useful.

Patient characteristics and clinical markers are predictive of chronic HBV-related clinical outcomes. What remains to be addressed is the extent to which these predictors represent clinically useful therapeutic targets or disease surrogates. Observational studies that report longitudinal measurements of these predictors and collect outcome data could better identify whether change in predictor status leads to change in outcomes. There was little evidence regarding the predictive ability of liver histology besides cirrhosis. The evidence for patients with HBV infection acquired later in life is weak and involves extrapolation from studies in people with perinatally acquired infection. Biological markers to monitor the effects of drug therapies have not been evaluated in RCTs, though several genetic or immunological markers to predict virological have begun to show promise.

Recent clinical guidelines classify patients into diagnostic groups based on HBeAg status, serum HBV DNA, ALT/AST levels, and biopsy results. Future studies should measure these factors and analyze data controlling or stratifying for these variables. Future studies would benefit from creating cohorts within existing diagnostic groups: inactive carrier, chronic hepatitis HBeAg-positive, chronic hepatitis HBeAg-negative, and chronic hepatitis with cirrhosis, and presenting key findings separately for these groups. Research is needed to identify valid surrogates and to demonstrate the effect of a treatment agent on the surrogate as well as clinical endpoints. Standardized assessment and determination of clinically meaningful changes, such as adopting a uniform scoring system for liver biopsies and deciding on a definition of what constitutes clinically meaningful change, are required. Standardized laboratory assays, methods to quantify intermediate markers of interest, and thresholds of abnormality are also required. Times to assess outcomes should be standardized by investigators.

## Conclusion

Adults with CHB infection are at increased risk for poorer health outcomes, though the absolute risk generally is small and requires many years to manifest. Presence of cirrhosis is the greatest risk factor leading to poor clinical outcomes. Interferons, reverse transcriptase inhibitors, and their combinations maintained short to mid-duration off-treatment improvements in selected intermediate outcomes but have not been demonstrated to improve clinical outcomes, to resolve hepatitis B infection, or sustain intermediate benefits over many years. Baseline patient and disease characteristics may modify response to treatments. Most drugs are relatively well tolerated, with few and generally mild adverse effects. Validated surrogate measures to assess treatment effectiveness do not exist. Long-term randomized controlled trials are needed to assess effects of antiviral agents on clinical outcomes and among patient subpopulation.