# Acknowledgments

We would like to thank our technical expert panel members, Dr. Miriam Alter, Dr. Gary Davis, Dr. Daryl Lau, Dr. Michael Sorrell, and Dr. Myron Tong for their scientific and clinical input throughout this project; Dr. Shilpa Amin, our Task Order Officer from AHRQ for her guidance throughout the project; as well as Dr. John Ward for reviewing and commenting on the draft. We also want to thank the librarians, Judith Stanke and Dr. Del Reed, for their contributions to the literature search; Maureen Carlyle and Marilyn Eells for editing and formatting the report; and Rebecca Schultz for her assistance with formatting the tables.