# Results

## Consensus Conference Question 1 What is the Natural History of Hepatitis B?

### EPC Question 1. What is the evidence that population characteristics (age, age at infection, geographic location, race/ethnicity, gender, positive family history) or clinical features (presence of coinfections, HBV viral load, change in HBeAg status, genotype, nonalcoholic, fatty liver disease, alcohol consumption, AST/ALT level, liver biopsy finding) associated with hepatitis B are predictive of hepatocellular carcinoma, liver failure, cirrhosis, liver-related death, and all-cause mortality?

Objectives. We outlined the evidence to which the above mentioned population characteristics and clinical features predict HCC, liver failure, cirrhosis, liver-related death, and all-cause mortality in people with hepatitis B.

Description of study characteristics. Our search strategy identified 614 articles from abstracts or full articles that were obtained to determine study eligibility. Additionally we included six articles that were found through hand-searching other articles or identified by members of our TEP. Each article was read by one of three extractors and included for further review if the article either appeared to meet the inclusion criteria or if inclusion was uncertain. In cases where inclusion was not obvious, consensus by the other reviewers was used to decide.

A total of 41 articles met inclusion criteria (Appendix E * Figure 1).^19^–^59^ These articles include populations from the United States, Argentina, Australia, Canada, China, Europe, Japan, Korea, and Taiwan.

* Appendixes and evidence tables cited in this report are provided electronically at http://www.ahrq.gov/downloads/pub/evidence/ pdf/hepb/hepb.pdf

Studies from the United States are over-represented; although the majority of research has occurred outside the Unites States, our review includes 14 publications representing eight unique populations within the United States. Appendix E Table 1 provides the descriptive characteristics in terms of the country, study design, number of patients, participant characteristics, length of followup, and outcomes assessed for each of the included studies. Table 1 provides a summary of the key risk factors and outcomes assessed, a semiquantitative estimate of risk magnitude (small <2-fold, moderate 2–5-fold, and strong ≥5-fold increased risk) and a statement regarding our confidence in the effect (inconclusive, low, medium, high) based on strength of evidence. Definitions for the ratings of magnitude and confidence are included in Table 1. We believe that the data available do not allow for more accurate quantitative risk estimates due to multiple patient and disease characteristics likely to affect prognosis.

Table 1 Factors associated with increased risk of selected outcomes in adults with chronic hepatitis B

Risk Factor | All cause Mortality | Liver Mortality | Hepatocellular Carcinoma | Cirrhosis
Increased Age (~10 years) | 3 studies^32,^,^51,56^ Low confidence Moderate effect | 1 study^48^ Low confidence Moderate effect | 6 studies^22,^,^23,47^–^49,53^ Medium confidence Small effect | 2 studies^29,53^ Medium confidence Small effect
Male | 4 studies^24,^,^47,^,^48,56^ High confidence Moderate effect | 4 studies^24,^,^27,^,^41,47^ High confidence Moderate effect | 8 studies^20,22^–^24,^,^30,^,^42,^,^46,49^ High confidence Moderate effect | 1 study^29^ Medium confidence Moderate effect
Geographic location and Asian race/ethnicity, early age of infection | | | 3 studies^35,^,^48,49^ Inconclusive
Family history of hepatocellular carcinoma | | | 3 studies^28,^,^34,54^ Low confidence Moderate effect
Nonalcoholic fatty liver disease
Modest alcohol consumption (drinkers average ~1 or fewer drinks per day) | | | 5 studies^23,^,^28,^,^30,^,^50,53^ Low confidence Small effect | 1 study^29^ Inconclusive
Heavy alcohol consumption
Cirrhosis (present vs. absent various types of detection) | | 2 studies^47,48^ Medium confidence Strong effect | 5 studies^22,^,^23,^,^46,^,^48,53^ High confidence Strong effect | N/A
Genotype C (vs. other [mostly A, B, D]) | | | 6 studies^22,^,^33,^,^49,^,^55,^,^57,59^ High confidence Moderate effect
Genotype F (vs. mostly A D) | | | 1 study^33^ Low confidence Strong effect
Precore mutation (A1896) | | | 3 studies^33,^,^48,49^ Low confidence Moderate effect
Basal core promoter mutation (T1762/A1764) | | 1 study^26^ Low confidence Small effect | 4 studies^33,^,^48,^,^49,57^ Low confidence Moderate effect
High HBV DNA load (<10ˆ4 copies mL, >10ˆ5) | 1 study^57^ Low confidence Small to moderate effect | 3 studies^25,^,^48,58^ High confidence Strong effect | 6 studies^22,^,^23,^,^49,^,^52,^,^59,168^ High confidence Strong effect | 1 study^29^ Medium confidence Strong effect
HBsAg loss | | | | 1 study^53^ Low confidence Small effect
HBeAg-positive status | | | 8 studies^23,^,^37,^,^48,^,^52,^,^53,^,^55,^,^57,59^ Medium confidence Moderate effect | 2 studies^29,53^ Medium confidence Small effect
Coinfection with HCV | | | 2 studies^20,43^ Low confidence Moderate effect
Coinfection with HIV | 2 studies^19,31^ Low confidence Small effect | 3 studies^19,^,^31,44^ Low confidence Strong effect
Coinfection with HDV | 2 studies^19,31^ Inconclusive | 3 studies^19,^,^31,44^ Low confidence Strong effect
Elevated ALT level (>45 U/L) | | | 3 studies^23,^,^53,57^ High confidence Moderate effect | 2 studies^29,53^ Medium confidence Small effect

Studies with references providing data for each outcome according to risk factor; level of confidence in estimate based on quality, quantity and consistency of evidence for the estimate of the relative risk magnitude is rated as “Inconclusive” (evidence insufficient to permit estimation of effect), “Low” (further research is likely to change the estimate), “Medium” (further research may change the estimate), “High” (further research is very unlikely to change the estimate); blank cells indicate no evidence available or does not apply. Magnitude of relative risk increase (RR) due to each factor for each outcome is estimated according to ranges from studies as “Small” (RR=1–2), “Moderate” (RR=2–5); and strong (RR=5 or greater)

Absolute risk of hepatocellular carcinoma, liver failure, cirrhosis, liver-related death, and all-cause mortality. Chronic carriers of HBsAg have substantially higher rates of HCC, cirrhosis, and death than people who are not HBsAg-positive.^21,^ ^24,^ ^30,^ ^39,^ ^45^ Figure 1 shows that infection with HBV can transition through multiple different pathways. Each pathway has differing degrees of risk for clinical outcomes. It is difficult to report the results of a population-based study in a way that captures each individual's fluctuations in disease severity and risk. This is particularly true during the longer-term followup for the studies that make up this review (at least 1 year and up to decades of followup). Therefore, while we briefly describe the absolute rate differences in HCC, cirrhosis and death among different HBsAg patient groups, the majority of this review will focus on the relative risk differences due to various patient and clinical characteristics.

Prior reports from Asia have estimated that the annual incidence of HCC is only 0.1 percent in asymptomatic HBsAg individuals, 1 percent in patients with CHB, but increases to 3–10 percent in patients with cirrhosis.^60^ In this same report, patients with CHB developed cirrhosis at a rate of 2 percent per year.

Reports from the United States have also shown similarly large differences in clinical event rates across diagnostic groups such as inactive HBsAg carriers, CHB without cirrhosis and CHB with cirrhosis. In a large U.S. cohort study of 400 chronic HBsAg patients (70 percent born in Asia and 24 percent born in North America), followed for over 7 years, results were reported by strata of inactive HBsAg carriers, CHB without cirrhosis, and CHB with cirrhosis (Figure 3).^48^ Among the 110 inactive carriers with an average age of 41 (standard deviation [SD]±16) years (who had no symptoms or signs of chronic liver disease, normal liver tests, and normal platelet counts) none developed HCC or died of a liver-related disease and only one died of any cause. Among the 151 patients with CHB but no cirrhosis (elevated serum aminotransferase levels and biopsy determined histologic grades of 1–3 and a stage of 1–3), 6 percent developed HCC and died from it, while another 2 percent died from nonliver related causes. Among those with CHB and cirrhosis, nearly 16 percent were diagnosed with HCC, and a total of 42 percent died during followup (all from liver-related causes).

Figure 3. Survival by hepatitis status, modified from Tong, 2006^48^

#### Population characteristics

Age and age at infection. Age is a complex variable to assess with respect to its relationship between HBV infection and risk of clinically important outcomes. For most clinically important outcomes increased age is related to higher risk of clinical events irrespective of HBV. However, with regard to age of infection, it is well known that individuals with earlier age of infection are more susceptible to chronic HBV infections and less likely to experience HBsAg loss. An example of the effect of age at infection is shown in a convenience study of U.S. military personnel exposed to a HBV contaminated yellow fever vaccine. Researchers noticed a very low rate of HCC-related mortality and hypothesized that immunocompetent adults rarely become carriers or go on to experience serious health consequences after a single exposure to HBV.^40^ Therefore, people who get exposed to HBV early in life will likely have worse outcomes than those exposed later in life. However, for any one individual the likelihood for events such as HCC, cirrhosis, liver failure, and death increases with age. So, ideally two pieces of information should be used to calculate risk: current age and age of infection. These two pieces of information provide estimates for whether or not an individual was exposed early on in life, the duration of chronic exposure, and increased risk of events due to older age. Unfortunately, we were unable to find studies that clearly identified the age of participants exposure, and few reported any information on duration of exposure. So the results we provide below with respect to the relationship between age and clinical outcomes should be interpreted with the knowledge that these results are confounded by age of exposure and duration of exposure effects that were unmeasured or just unreported.

One additional factor that might be confounding age-related associations is that selection into a study might be different depending on the age of the participant. A large study of HCC cases in Hong Kong found that younger cases (≤40 years of age) were more likely to present with more pain, hepatomegaly, and more advanced stage with frequent pulmonary metastasis than older HCC cases (>40 years of age).^32^ While the survival rate (6.6 versus 8.3 months, p=0.77) was similar for younger versus older HCC cases, this study makes clear that assessing differences in death rate by age should take severity of disease at diagnosis into account.

Overall, age does appear to be associated with poorer outcomes. In studies that have controlled for other potential confounders such as disease severity, age is often found to increase the risk of poor outcomes. Among a U.S. case control study of HCC in HBsAg-positive individuals (70 percent born in Asia), each 1 year increase was associated with 5 percent relative increased odds of HCC (odds ratio [OR], 1.05, 1.02; 1.08).^49^ Similarly, among Alaska Native people each 1 year increase in age increased the rate of HCC by 4 percent (hazard ratio [HR], 95 percent CI 1.04, 1.0; 1.07).^37^ Some of the largest and best controlled non-U.S. studies have also confirmed the finding of age and poor outcomes, particularly for HCC. Even after controlling for differences in gender, cirrhosis status, HBV genotype, and HBV viral load, a large prospective study from Hong Kong found that each year of age increased the relative rate of HCC by 8 percent (95 percent CI 5–11 percent).^22^ The Taiwanese REVEAL Study also found increased relative rates of HCC per year of age to be 6–11 percent depending on the severity of HBV.^23^ The relative rates for cirrhosis also increased in the REVEAL study by approximately 3–5 percent per year of age.^29^

In conclusion, increased age of the patient is associated with poorer long-term clinical outcomes due to CHB. Limited evidence suggested medium confidence of a small effect on HCC and cirrhosis and low confidence of a moderate effect on mortality outcomes. There is inconclusive evidence regarding the extent to which this association between age and clinical outcomes is explained by duration of infection, age of infection, comorbidities in older individuals and other factors that tend to be different between older and younger patients.

Gender. Males are much more likely to have chronic HBV than females; and the rate of clinical outcomes among those with HBV in terms of HCC,^20,^ ^22,^ ^24,^ ^25,^ ^30^ cirrhosis,^29^ and death^24,^ ^27,^ ^41,^ ^48,^ ^56^ are consistently several fold higher in males than in females. Actual magnitudes of effect ranged from 1.5–7.6 fold higher rates of outcomes in men than in women, with most studies reporting at least 2–3 fold differences, even after adjusting for many important potential confounders such as age, severity of liver disease, and other health related factors. Results tended to be somewhat stronger for HCC than death.

In conclusion, there is high confidence that males on average have increased rates of death and HCC and medium confidence of an increased rate of cirrhosis. The magnitude of effect is on average greater than 2-fold in men compared to women for all of these outcomes. It is unclear what the mechanism is for this substantial effect by gender.

Geographic location, race/ethnicity. HBV infection is endemic in several locations around the world, including portions of Asia, Africa, and also among Alaska Natives in the United States. While geographic location is important in terms of exposure to HBV infection, we found little evidence that would allow us to separate out the effects of geographic location of birth and race/ethnicity. Geographic regions have different portions of early HBV transmission and different distributions of HBV genotypes. Further complicating geographic differences in outcomes related to HBV are the economic and health systems resources available in different regions.

Among a U.S. case control study of HCC in HBsAg-positive individuals, Asians did not have a significantly increased rate of HCC compared to non-Asians (OR, 95 percent CI 1.6, 0.6; 4.2). However, the power to detect clinically meaningful differences was limited and this number was not adjusted for known differences in age at infection or other key characteristics.^49^ Two studies also reported geographic/ethnic differences in Alaska Native populations.^35,^ ^37^

In conclusion, there is high confidence that certain geographic locations are associated with increased HBV infection. Among people with CHB it is inconclusive that geographic location or race/ethnicity contribute meaningfully for the prediction of clinical outcomes.

Positive family history. Few studies reported information about the effect of positive family history and outcomes such as HCC, cirrhosis, and liver-related death. It is nearly impossible to sort out any independent effect for family history outside of the effects already mentioned based on age of infection and patient's geographic location or race/ethnicity.

One study from Haimen City, China, reported 2.3 fold (p <0.001) greater odds of positive family history of HCC among cases of HCC compared to controls.^28,^ ^34^ This study did not report results specific for HBsAg-positive subjects, but it did claim the results were similar between HBsAg-positive and negative subjects. Another study from Taiwan found that HCC cases were at 2.8 fold greater odds of having a family history of HCC compared to controls.^54^ Neither study was able to adequately control for shared environmental factors between family members, but both studies do suggest that propensity for HCC might have a heritable component.

In conclusion, a positive family history of HCC is associated with a moderate increased risk of HCC (low confidence), but the extent this increased risk is independent of age of infection and duration of disease is unclear.

#### Clinical features

Presence of coinfections: Human immunodeficiency virus (HIV), Hepatitis C virus (HCV), Hepatitis delta virus (HDV). Coinfection with HIV, HCV or HDV has been found to be associated with poorer clinical outcomes. However, the number of studies reporting this issue for any one type of coinfection is small, and associations are not consistent across different types of coinfection, so there is a low level confidence in the magnitude of these associations.^19,^ ^31,^ ^43,^ ^44^

Among HIV patients in Europe, Argentina, and Israel, HBV coinfection increased all-cause and liver-related death rates 1.5 and 3.6 times, respectively, above that of HIV infection alone.^31^ Thio and colleagues^44^ found that among the large U.S. Multicenter AIDS Cohort Study (MACS) of 5,293 men who had sex with men, HIV status dramatically increased the rate of liver-related mortality in men positive for HBsAg. The liver-related mortality rate was 14.2 per 1,000 person years, which was approximately ten-fold higher than men with only HBsAg or HIV alone. However, the MACS study does not provide evidence on the extent to which the dramatically higher rate of liver-related death is due to more severe hepatitis B disease in the men with coinfection with HIV.

Among Japanese blood donors positive for HBV, those with coinfection with HCV had a 3-fold increase in HCC independent of age, sex, and ALT level.^43^ However, a study by Amin and colleagues from Australia found similar rates of HCC in people with both HBV and HCV compared to those with HBV alone.^20^

In a U.S. study of 231 developmentally disabled patients with chronic HBsAg-positive status living in institutional facilities, 65 patients were also antiHDV-positive.^19^ In multivariable models, patients positive for antiHDV were nearly 12 times (95 percent CI 1.4; 97.8) more likely to die of liver-related causes, but all-cause mortality was not significantly increased. The evidence for this association is weak because there were only eight liver-related deaths and it is uncertain how generalizable the results from an institution are to other environments.

In conclusion, estimates regarding coinfection and clinical outcomes could only be made with low confidence due to the paucity or inconsistency of the data. Coinfection with either HIV or HDV was associated with strongly increased liver-related mortality. Coinfection with HCV was associated with moderately increased HCC risk.

HBV viral load. Higher HBV viral load has been consistently shown to be associated with poorer clinical outcomes, particularly when comparing very low or undetectable levels of DNA to levels above 10^5^ or 10^6^ copies/mL. However, having low or undetectable DNA does not eliminate the risk of clinical outcomes.^52^ Furthermore, much less well known is the extent to which reductions in viral load lead to improvements in clinical outcomes.

The evidence for the association between HBV viral load and clinical outcomes was primarily from several large studies in Taiwan^23,^ ^29,^ ^52,^ ^54^ and China.^22,^ ^25^ However there were two articles from the United States that also found increased HCC cases^49^ and increased non-HCC liver-related death in those with high viral loads.^48^

The Taiwan REVEAL Study found that in multivariable models adjusted for age, gender, smoking, alcohol use, HBeAg status, ALT level, and cirrhosis the risk of HCC began increasing slightly for people with >10^4^ to <10^5^ copies/mL and the risk of HCC was around 6-fold higher for people with viral loads above 10^5^ or >10^6^ compared to people with undetectable viral loads.^23^ This same study reported a similar association between viral load and risk of cirrhosis.^29^ Additional reports from this study have also shown a strongly increased rate of liver-related mortality, that in turn leads to a modest (approximately 2-fold) multivariable adjusted increased all-cause death rate in those with HBV DNA ≥10^5^ compared to those with HBV DNA <10^5.58^ There was no significant increase in the nonliver related death rate for those with elevated HBV DNA level. Another study from Taiwan found a similar HCC association with some increase in risk beginning above 10^4^ copies/mL and a substantial 7-fold increase in risk above 10^6^ copies/mL.^54,^ ^59^ HCC death and chronic liver disease death have also been reported in a study from China to follow a similar trend.^25^

In the REVEAL study the risk for HCC appeared to increase more steeply along the viral load gradient for groups with lower baseline risk of clinical outcomes.^23^ For example, among the subset of people with normal ALT levels, no liver cirrhosis and negative for HBeAg there was a 4.5-fold increased risk at >10^4^ to <10^5^ copies/mL and a greater than 11 fold increased risk above >10^5^ copies/mL compared to people with normal ALT levels, no liver cirrhosis, negative for HBeAg and no detectable HBV DNA. It is likely that this steeper gradient of relative risk is driven largely by the much lower absolute rate of HCC in the low risk reference group. In a study from Hong Kong where the “low risk” HBV viral load group was defined more broadly as having levels <10^4.5^ copies/mL and the “high risk” group was define as >10^6.5^ copies/mL, only around a 2-fold increase in rate of HCC was found, after accounting for age, gender, cirrhosis, and albumin (additional adjustment for HBV genotype did not substantially alter the association).^22^ Another study from Taiwan also found that among people positive for HBsAg and negative for HBeAg, HCC cases were much more likely than controls to have elevated DNA; however, the greatest absolute proportion of both cases and controls had undetectable HBV DNA.^52^

Results from the United States are consistent with the results from Asian countries, showing an increased rate of HCC and liver-related death across a gradient of HBV viral load.^48,^ ^49^ In one U.S. study of 101 HCC cases of HBsAg-positive individuals, increased viral load was strongly associated with increased likelihood of HCC; however, none of the chronic inactive HBV controls had viral loads in the “high viral load group” (>10^6^ copies/mL), so the magnitude of effect due to “high viral load” could not be estimated.^49^ Another U.S. cohort study from the same group of researchers found that among 400 chronic HBsAg patients high baseline HBV DNA viral load significantly increased the odds of nonHCC related liver death by nearly 5-fold (OR, 95 percent CI 4.7, 1.2; 20.4) independent of age and gender.^48^

In conclusion, increased HBV DNA viral load is strongly associated with increased HCC (high confidence) and liver-related mortality (high confidence) even after accounting for baseline cirrhosis, HBeAg status, and ALT levels. However, there was only low confidence of a small to moderate association with all cause mortality. We also found a strong association between HBV viral load and cirrhosis (medium confidence). We found no evidence from these large observational studies regarding whether reduction in HBV DNA viral load is associated with better outcomes.

HBV genotype. Evidence for the impact of HBV genotypes on clinical outcomes for HBV is limited. It is clear that the prevalence of different genotypes varies substantially by geographic location, but more research is needed to determine the extent to which HBV genotype modifies the natural history of HBV related outcomes. What is available indicates that there likely are some differences in at least HCC rates according to genotype. Among a U.S. case control study of HCC in HBsAg-positive individuals, patients with HBV genotype C had 4-fold greater odds of HCC compared to other genotypes (genotypes A, B, and D). However, this association remained strong but was not statistically significant after accounting for age, gender, and basal core and precore mutations (OR 3.3, 95 percent CI 0.9; 12.1).^49^ A large study from Taiwan found similar associations of 3–6-fold increased risk of HCC among people with the C genotype only compared to people with the B genotype only.^57,^ ^59^ People with both B and C genotypes were at an intermediate risk.^59^ The results from this study remained statistically significant and only modestly attenuated following multiple adjustment. In a large study from Hong Kong the HBV C genotype was associated with only a modest 1.5-fold (95 percent CI 1.2; 2.0) increased rate of HCC compared to genotype B after accounting for age, gender, cirrhosis, viral DNA load, and albumin.^22^ Finally, among Alaska Native people the odds of HCC were 4.7 times greater in patients with the A genotype (95 percent CI 1.4; 16.0) and 11.7 times greater in patients with the F genotype (95 percent CI 5.4; 25.4) compared to those with the D genotype.^33^

In conclusion, HBV genotypes may be associated with differing risk of clinical outcomes. Genotype C moderately increases risk of HCC compared to genotypes A, B, and D (high confidence), and genotypes A (moderate effect) and F (strong effect) may increase risk compared to D (low confidence).

HBsAg loss. Only one study was identified that reported HBsAg loss and clinical outcomes, and this study had low power to detect meaningful differences in risk.^53^ In a large Taiwanese study of asymptomatic carriers at baseline followed for an average of 7 years, those with HBsAg loss had a 40 percent reduction in risk of cirrhosis, but this was not statistically significant (95 percent CI 79 percent reduction ranging to a 64 percent increase in risk of cirrhosis), after adjusting for age, HBeAg status and AST/ALT levels.^53^

In conclusion, HBsAg loss may be associated with a reduction in risk of cirrhosis (low confidence). There is no evidence whether or not HBsAg loss is associated with other clinical outcomes.

HBeAg status. HBeAg-negative status in a population study tends to be a marker of inactive carrier status, particularly when ALT levels are normal and HBV viral load is low (Figure 1). However, HBeAg-negative CHB can also occur (it is indicated by elevated HBV DNA and ALT). Therefore, it becomes more difficult to interpret the association between HBeAg status and outcomes without also using ALT and HBV DNA levels to help to classify people into either inactive carrier status or HBeAg-negative status. Since it is well known that inactive carriers have lower rates of clinical outcomes than those with either HBeAg-positive or negative chronic active hepatitis, the most interesting research questions may be to determine the impact of HBeAg status in people with active hepatitis and the effect of HBeAg reversion on clinical outcomes. Unfortunately, we found few studies that classified people into groups of chronic inactive hepatitis and chronic active hepatitis and then looked at the effect of HBeAg within those groups.

While several studies have reported a consistently higher rate of outcomes among people who are HBeAg-positive compared to HBeAg-negative,^23,^ ^29,^ ^37,^ ^53,^ ^57,^ ^59^ we were unable to assess the effect of the HBeAg independent of its role as a marker of chronic active versus chronic inactive hepatitis. One study in Taiwan found the incidence rate for HCC was 3.6 times higher in HBsAg-positive people who were also HBeAg-positive compared to those who were HBeAg-negative.^52^ From the REVEAL study in Taiwan this increased risk of HCC (HR 2.6, 95 percent CI 1.6; 4.2) and cirrhosis (RR 1.7, 95 percent CI 1.3; 2.9), for HBeAg-positive people persisted following adjustment for age, gender, HBV viral load, and ALT level.^23,^ ^29^ A third large Taiwanese study also reported 2–3-fold increased risk of HCC among people with HBeAg-negative CHB.^57,^ ^59^

Among Alaska Natives, reversion to HBeAg positivity or multiple switches in HBeAg status was associated with increased risk for hepatocellular carcinoma (HR 2.6, 95 percent CI 1.3; 5.4), after adjustment for potential confounders.^37^ Another U.S. study by Tong and colleagues that classified all patients into “inactive carriers,” “chronic hepatitis,” or “cirrhotic,” found that patients who were positive for HBeAg at baseline had similar rates of HCC and all cause death as patients antiHBeAg at baseline.^47^

In conclusion, HBeAg-positive status is associated with moderately increased HCC (medium confidence) and small increases in cirrhosis (medium confidence) independent of other disease factors such as HBV viral load and ALT level.

Basal core promoter (T1762/A1764) or precore mutation (A1896). Only a few recent studies have attempted to look at the extent to which basal core promoter (BCP) mutations and precore (PC) mutations impact clinical outcomes.^26,^ ^33,^ ^48,^ ^49,^ ^57^ This is one area where much of the information came from U.S. based studies.

Among Alaska Natives there was no significant association between either BCP or PC mutations and HCC. However, the basal core mutations did vary significantly by HBV genotype.^33^ Among a U.S. case control study of HCC in HBsAg-positive individuals, the A1896 PC mutation was associated with a nearly 4-fold increase in HCC and the T1762/A1764 mutation was associated with an 11-fold increase in HCC compared to wild types for both of these factors, independent of age, gender, race, and HBV genotype.^49^ In a U.S. cohort study of 400 chronic HBsAg patients the odds of developing HCC were 2.9 times greater (95 percent CI 1.2; 7.6) for those with the BCP mutation and 4.2 times greater (95 percent CI 1.5; 19.6) for those with the A1896 PC mutation compared to those with wild type basal and PC mutations, respectively.^48^ In a large study out of China the HCC death rate was 1.40 (95 percent CI 1.06; 1.85) times greater in those with 1762T/A1764 BCP mutations compared to other HBsAg-positive subjects.^26^ Likewise a large study from Taiwan found a 1.92-fold (95 percent CI 1.14; 3.25) increased risk of HCC, independent of HBV genotype, ALT level and HBeAg status.

In conclusion, the BCP mutations (T1762/A1764) and the PC mutation (A1896) are associated with moderately increased HCC rates and BCP is associated with increased liver-related death rates (low confidence).

Cirrhosis. Cirrhosis has been shown to be a consistently strong predictor of HCC development and death in many studies. It has been reported for decades even within the United States that survival is greatly reduced in patients with cirrhosis compared to patients without cirrhosis.^47,^ ^51^ As early as 1984 Weissberg and colleagues were reporting that the 5-year survival rate among patients with CHB could range from 97 percent in patient without cirrhosis to 55 percent in patients with chronic active hepatitis and cirrhosis.^51^ In a study by Tong and colleagues, biopsy determined cirrhosis was associated with a 3.6-fold (95 percent CI 1.6; 8.9) increased odds of developing HCC independent of age, serum albumin, and baseline platelets. In the same study, the independent association was even stronger for all-cause death and nonHCC liver-related death (OR 14.2, 95 percent CI 3.4; 111.8 and 7.3, 95 percent CI 1.3; 69.56 respectively).

The findings from U.S. studies are consistent with the large studies from Taiwan and China which have consistently reported much higher rates of HCC and death in cirrhotic individuals.^22,^ ^23,^ ^53^ Rates are often nearly 10-fold greater in people with cirrhosis even after adjustment for other markers of disease severity such as elevated ALT or HBV viral load. Few large studies had biopsies in all of their patients and instead relied on ultrasound detected cirrhosis which still strongly predicted increased rates of clinical outcomes.

In conclusion, cirrhosis is a strong predictor of HCC (high confidence) and liver-related death (medium confidence).

Nonalcoholic fatty liver disease. No studies were identified that reported the impact of nonalcoholic fatty liver disease on clinical outcomes in people with chronic HBV.

Alcohol consumption. Alcohol consumption was not frequently reported as an important factor in models predicting clinical outcomes from HBV. Studies that did include measures of alcohol consumption tended to use variables that indicate any consumption or years of consumption and did not try to isolate people with heavy alcohol consumption. The association between alcohol consumption and clinical outcomes reported in the identified studies appeared modest at best with effect sizes around 1.5-fold increased risk of HCC. In a large Taiwanese study of over 2,000 people, alcohol consumption and duration of alcohol use were only weakly associated with HCC development. Compared to people who never drank alcohol, those who drank for over 20 years only had a 1.33-fold increased risk of HCC (95 percent CI 0.75; 2.43) adjusting for age, family history of HCC, HCV status, baseline liver function, ethnicity, and education.^50^ However, there did appear to be a potential interaction with smoking status such that those with increased alcohol and smoking use had elevated HCC.^53^ Similarly, size associations were reported in two other studies of 1.5 and 1.6-fold increased risk of HCC in those who consumed about two drinks per day in one study^30^ or reported any alcohol consumption in the other study.^23^

While modest consumption of alcohol does not appear to be a strong predictor of clinical outcomes related to HBV, cirrhosis was a consistently strong predictor of HCC and death. So while the studies identified did not break out causes of cirrhosis, it might be reasonable to assume that heavy drinking that leads to liver cirrhosis may be an important factor in clinical outcomes, even if modest drinking is not.

In conclusion, moderate alcohol consumption in people chronically infected with HBV appeared to be a weak predictor of increased HCC. There is low confidence in this association. Little evidence exists regarding the association between heavy alcohol use and clinical outcomes in people with chronic HBV.

AST and ALT levels. Few studies reported associations between elevated aminotransferase levels and clinical outcomes. Those that did tended to report increased risk of outcomes. This increased risk may be in part explained by other factors. Among a large Taiwanese study of asymptomatic carriers at baseline followed an average of 7 years, those with either elevated AST or ALT levels had a 3.1-fold (95 percent CI 1.0; 10.0) increased risk of HCC and a 3.7 fold (95 percent CI 2.3; 6.0) increased rate of cirrhosis, independent of age, HBeAg status, and baseline cirrhosis (for the HCC results).^53^ Another study from Taiwan, also found a similar association with HCC 2.5-fold (95 percent CI 1.1; 4.3).^57^ Also from Taiwan, the REVEAL study reported an unadjusted 4-fold increased risk of HCC with ALT levels >45 U/L, but after adjusting for age, gender, smoking, alcohol, HBeAg, cirrhosis, and HBV viral load the association was completely attenuated (HR 1.1, 95 percent CI 0.7; 1.7).^23^ In the same study, the association between elevated ALT and cirrhosis remained significant but only modest in strength after multiple adjustment (HR 1.5, 95 percent CI 1.1; 2.1).^29^

In conclusion, ALT is moderately associated with increased risk of HCC (high confidence) and weakly associated with cirrhosis (low confidence). These associations appear to be largely explained by accounting for baseline cirrhosis, HBeAg status, and HBV viral load (low confidence).

## Consensus Conference Question 2 What are the Benefits and Risks of the Current Therapeutic Options for Hepatitis B with Defined or Continuous Courses of Treatment?

### EPC Question 2a. What is the efficacy (or effectiveness) of antiviral therapy in treating adults with chronic hepatitis B?

Characteristics of included studies. Ninety-three articles (Appendix E Figure 1)^10,^ ^61^–^145,^ ^169^–^175^ represented 60 unique randomized trials of interferon alfa-2b,^61^–^92^ peginterferon alfa-2a,^93^–^97^ adefovir,^10,^ ^110^–^120^ peginterferon alfa-2b,^98^–^109^ entecavir,^121^–^126^ lamivudine,^64,^ ^67,^ ^95,^ ^96,^ ^119,^ ^127^–^142^ or telbivudine.^120,^ ^127,^ ^143,^ ^144^ Studies enrolled between 20 and 1,367 patients (Table 2). Males constituted 78 percent of enrollees. Study duration lasted 69 weeks (range 17–208) with treatment duration averaging 44±22 weeks, and followup off the treatment 98±158 weeks for studies that reported outcomes during followup off treatment (Appendix E. Table 2). Nearly all enrollees were Asian (64 percent) or white (30 percent) ethnicity/race. The estimated mean or median duration of infection was reported in eight studies and ranged from about 2–6 years. However, the individual patient duration of infection ranged from 6 months to 20 years.^61,^ ^63,^ ^66,^ ^69,^ ^81,^ ^83,^ ^84,^ ^86,^ ^87,^ ^90^

Table 2 Treatments of hepatitis B: Overview of randomized controlled trials

Study Characteristic | Percent or Mean (Range) | Number of Subjects | Number of Trials Reporting
All studies (# subjects) | 20–1,367 | 11,144 | 59
Weighted mean age | 37 (24–58) | 7,884 | 40
Gender, male (%) | 78 | 8,408 / 10,721 | 58
Race, Asian (%) | 64 (0–100) | 5,097 / 7,954 | 27
Race, White (%) | 30 (0–98) | 2,219 / 7,954 | 27
Race, Black (%) | 1 (0–24) | 111 / 7,954 | 27
Race, Other (%) | 5 (0–8) | 184 / 5,380
e Antigen-positive (%) | 81 (2–100) | 7,453 / 9,160 | 48
e antigen-negative (%) | 64 (19–100) | 2,828 / 4,434 | 17
Mean ALT level (IU/L) | 139 (77–284) | 6,917 | 33
Median ALT level (IU/L) | Range 56–170 | 1,327 | 7
Study duration (weeks), therapy and followup combined | 69 (17–208) | 10,606 | 56
Treatment naive | All subjects | 2,388 | 13
Treatment resistant | All subjects | 1,241 | 11
Study withdrawals (%) | 7 (0–35) | 712 / 10,199 | 50
Withdrawals due to adverse events (%) | 3 (0–16) | 199 / 7,697 | 36
Cirrhosis (%) | 21 (5–65) | 1,258 / 6,047 | 31
Studies ≥1 biopsy | All subjects | 8,466 | 43
HBV genotype
A | 13 (0–34) | 609 / 4,800 | 11
B | 19 (0–32) | 913 / 4,800 | 11
C | 42 (15–100) | 2,002 / 4,800 | 11
D | 19 (0–46) | 906 / 4,800

Studies enrolled predominately HBeAg-positive individuals. Fifty-four reports included more than 98 percent of HBeAg-positive patients.^61,^ ^62,^ ^64,^ ^65,^ ^67^–^70,^ ^72,^ ^73,^ ^75,^ ^77,^ ^78,^ ^80,^ ^83^–^88,^ ^90,^ ^92,^ ^94,^ ^96,^ ^98^–^109,^ ^112,^ ^113,^ ^116,^ ^119,^ ^120,^ ^122,^ ^126,^ ^127,^ ^129^–^131,^ ^134^–^136,^ ^138,^ ^140,^ ^145^ Eleven reports described outcomes in HBeAg-negative patients.^10,^ ^71,^ ^74,^ ^76,^ ^79,^ ^81,^ ^91,^ ^93,^ ^95,^ ^110,^ ^111,^ ^142^ Other authors reported outcomes without differentiating between HBeAg-positive and negative patients (Appendix E, Table 2).

In 16 reports investigators reported outcomes for individuals who were naïve to antiviral drugs patients.^68,^ ^72,^ ^75,^ ^76,^ ^85,^ ^90,^ ^94,^ ^106^–^108,^ ^115,^ ^120,^ ^122,^ ^126,^ ^136,^ ^139^ Seven reports enrolled patients independent of previous treatment status or tested new drugs on patients resistant to previous treatments.^67,^ ^77,^ ^92,^ ^118,^ ^119,^ ^125,^ ^141^ Cirrhosis was assessed at baseline in 32 studies^61^–^64,^ ^67,^ ^73,^ ^74,^ ^77,^ ^80^–^83,^ ^85,^ ^88,^ ^91,^ ^92,^ ^94^–^96,^ ^99,^ ^103^–^105,^ ^110,^ ^121,^ ^122,^ ^132,^ ^135,^ ^136,^ ^138,^ ^139,^ ^142^ and was noted in 21 percent these enrollees. Authors reported HBV genotype in 13 studies.^94,^ ^96,^ ^99,^ ^104,^ ^107,^ ^109,^ ^114,^ ^121,^ ^122,^ ^124,^ ^125,^ ^139,^ ^143^ Genotype C was the most common (42 percent).

Sixteen of 93 articles reported mortality, liver related death, hepatocellular carcinoma, hepatic decompensation, or cirrhosis (Appendix E Table 3).^83,^ ^85,^ ^86,^ ^90,^ ^91,^ ^96,^ ^106,^ ^107,^ ^111,^ ^121,^ ^122,^ ^124^–^126,^ ^132,^ ^141^ The largest study enrolled 814 HBeAg-positive patients and lasted 72 weeks.^96^ Few events were reported in these studies. None were of sufficient size or duration to adequately assess the effect of treatments on these outcomes. (Appendix E. Table 4).

Clinical outcomes Only 16 RCT reported on clinical outcomes: (mortality [13]; hepatocellular carcinoma [4]; hepatic decompensation [3]; or cirrhosis [2]). None were of sufficient size or duration or were designed to assess clinical outcomes. A small number of clinical events and studies compared different drugs and patients, generally precluding pooling. Investigators primarily designed studies to examine the effects of antiviral therapies alone or in combination compared to other antiviral therapies (or placebo) on intermediary biochemical, virological, or histological outcomes. Most studies assessed these as short-mid-term outcomes during the course of treatment or at treatment conclusion (typically 1 year or less). Sustained efficacy of these intermediary outcomes was reported in the minority of studies and when reported typically was less than 1 year off treatment. The majority of RCTs that reported clinical outcomes described zero or a small number of clinical events (Appendix E Table 4). The longest study duration reporting mortality or cirrhosis (treatment + followup) was less than 3 years and the longest study assessing mortality was 130 weeks (Table 3, Appendix E Figure 2).

Table 3 Effects of drug therapies for chronic hepatitis B on clinical outcomes

Active Treatments vs. Control Treatment | Treatment Duration/Followup Off Therapy, Weeks | Studies/Subjects Enrolled | Estimates (95% CI) *Dose Response Heterogeneity: p Value/I Squared, % | Level of Evidence/Comments
Liver related death
Lamivudine vs. placebo^132^ | 130/0 | 1/651 | 0.00 (-0.01; 0.01) (RD) | Low. Sparse data (0 events in both groups) No effect of LAM on liver related death
Mortality
Lamivudine vs. placebo^132^ | 130/0 | 1/651 | 0.00 (-0.01; 0.01) (RD) | Low. Sparse data (0 events in control group) No effect of LAM on mortality
Interferon alfa-2b vs. placebo^83^ | 16/48–64 | 1/40 | NS at the end of treatment and after followup | Low. Sparse data (small N of events) No effect of Interferon alfa 2 B on mortality
Adefovir dipivoxil^111^ | 114 vs. 240/0 | 1/125 | 0.33 (0.01; 8.10) (RR) | Low. Sparse data (0 events at second time point, no formal control) Length of adefovir therapy did not affect mortality
Entecavir^124^ | 48/0 | 1/89 | NS among all compared doses No * | Low. Sparse data (small number of events) No dose response effect on mortality
Entecavir vs. lamivudine^121,^,^122,124^–^126^ | 48–96/0–28 | 5/2476 | NS in all studies -0.003 (-0.008;0.002) (RD) 0.7/0% | Low. Sparse data (small N of events) No differences between entecavir vs. lamivudine on mortality
Interferon alfa 2b+corticosteroid vs. interferon alfa 2b^86^ | 24/0 | 1/37 | -0.11 (-0.27; 0.06) (RD) | Low. Sparse data (0 events in active group) No differences of pretreatment with steroid and interferon alfa-2b vs. interferon alfa-2b on mortality
Interferon alfa 2b+corticosteroid vs. symptomatic treatment^70^ | 24/48 | 1/20 | -0.10 (-0.34; 0.14) (RD) | Low. Sparse data (0 events in active group) No differences of pretreatment with steroid and interferon alfa-2b on mortality
Interferon alfa 2b^86,90^ | 24–48/0–24 | 2/76 | NS among all compared doses No * | Low. Sparse data (0 events in active group) No dose response effect on mortality
Peginterferon alfa-2a+placebo vs. lamivudine^96^ | 48/8 | 1/543 | 0.00 (-0.01; 0.01) (RD) | Low. Sparse data (0 events in both groups) No differences between peginterferon alfa-2a and lamivudine on mortality
Peginterferon alfa-2a+lamivudine vs. lamivudine^96^ | 48/8 | 1/543 | 0.01 (0.00; 0.03) (RD) | Low. Sparse data (0 events in control group) No differences between peginterferon alfa-2a combined with lamivudine vs. lamivudine alone on mortality
Peginterferon alfa-2a+lamivudine vs. peginterferon alfa-2a^96^ | 48/8 | 1/543 | 0.01 (0.00; 0.03) (RD) | Low. Sparse data (0 events in control group) No differences between peginterferon alfa-2a combined with lamivudine vs. peginterferon alfa-2a alone on mortality
Peginterferon alfa-2b+lamivudine vs. amivudine^106^ | 50–60/56–64 | 1/100 | 0.02 (-0.03; 0.07) (RD) | Low. Sparse data (0 events in control group) No differences between peginterferon alfa-2b combined with lamivudine vs. lamivudine on mortality
Incident cirrhosis
Interferon alfa-2b vs. no treatment^83^ | 16/48–64 | 1/40 | -0.05 (-0.21; 0.11) (RD) | Low. Sparse data (small number of events) No effect of interferon alfa-2b on cirrhosis
Interferon alfa 2b+corticosteroid vs. interferon alfa 2b^85^ | 24/24 | 1/56 | -0.06 (-0.24; 0.11) (RD) | Low. Sparse data (small number of events) No differences of pretreatment with steroid and interferon alfa-2b on incidence of cirrhosis
Hepatic decompensation
Lamivudine vs. placebo^141^ | 80/0 | 1/74 | 0.05 (-0.11; 0.22) (RD) | Low. Sparse data (small number of events) No effect of lamivudine on liver decompensation
Lamivudine vs. no treatment^141^ | 80/0 | 1/74 | 0.00 (-0.12; 0.12) (RD) | Low. Sparse data (small number of events) No effect of lamivudine on severe liver decompensation
Peginterferon alfa-2b+lamivudine vs. lamivudine^106^ | 52–60/57–72 | 1/100 | 0.00 (-0.04; 0.04) (RD) | Low. Sparse data (0 events in both groups) No differences between combined peginterferon alfa-2b with lamivudine vs. lamivudine alone on liver decompensation
Entecavir vs. lamivudine^122,126^ | 52–96/0–24 | 2/709 | NS after different treatment duration | Low. Sparse data (0 events in active group) No differences between entecavir vs. lamivudine on liver decompensation
HCC
Lamivudine vs. placebo^132^ | 130/0 | 1/651 | -0.04 (-0.07; 0.00) (RD) | Low. Significant protective effects of active drug after adjustment for country, sex, baseline Alanine aminotransferase level, Child-Pugh score, and Ishak fibrosis score (HR = 0.49, 95% CI 0.25; 0.99) No effect of lamivudine on HCC
Interferon alfa-2b vs. placebo^91^ | 96/0 | 1/42 | 0.05 (-0.07; 0.17) (RD) | Low. Sparse data (0 events in control group) No effect of Interferon alfa-2b on HCC
Adefovir dipivoxil^111^ | 114 vs. 240/0 | 1/250 | 0.03 (-0.01; 0.07) (RD) | Low. Sparse data (small number of events at first time point, no formal control) Length of adefovir therapy did not affect HCC
Interferon Alfa 2b+corticosteroid vs. interferon alfa 2b^85^ | 24/24 | 1/56 | -0.02 (-0.28; 0.24) (RD) | Low. No difference on active hepatitis between interferon alfa-2b with pretreatment using corticosteroid vs. interferon alfa-2b

Bold - significant association at 95% confidence level; RD - absolute risk difference; RR - relative risk

Mortality. Thirteen studies assessed mortality (Table 3).^70,^ ^83,^ ^86,^ ^90,^ ^96,^ ^106,^ ^111,^ ^121,^ ^122,^ ^124^–^126,^ ^132^ The longest study lasted 130 weeks and enrolled 651 HBeAg-positive patients.^132^ No study reported a statistically significant improvement in mortality due to any treatment, though few deaths occurred. Studies were not designed or powered to assess statistically significant differences. Medications evaluated included lamivudine,^132^ entecavir,^121,^ ^122,^ ^124^–^126^ interferon alpha 2b,^70,^ ^86,^ ^90^ peginterferon alfa-2a,^96^ peginterferon alfa-2b,^106^ and adefovir.^111^ Studies enrolled only HBeAg-positive^70,^ ^83,^ ^86,^ ^90,^ ^96,^ ^106,^ ^126^ or HBeAg-negative patients;^111,^ ^121^ some reported proportions of patients with baseline cirrhosis.^83,^ ^96,^ ^121,^ ^122,^ ^125,^ ^132^ One multicenter, double-blind RCTs of 651 Chinese patients (58 percent HBeAg-positive, 61 percent with cirrhosis, median ALT=69.3 U/L, median HBV DNA=14.9 mEq/mL), failed to demonstrate a statistically significant effect of lamivudine for 130 weeks versus placebo on liver related death or all-cause mortality (RR=2.47, 95 percent CI 0.12; 51.25).^132^ Very few deaths occurred (none in the control group) (Table 3).

The largest study was a multi-arm trial that involved 814 HBeAg-positive patients, lasted 72 weeks, and was conducted at 67 sites in Asia, Australia, Europe, and North and South America. Authors reported no difference in mortality between combination peginterferon alfa-2a combined with lamivudine compared to either lamivudine or peginterferon alone during 48 weeks of treatment and 24 weeks of treatment free followup.^96^ However, very few deaths occurred in any of the groups (Appendix E Figure 3). Several reports compared entecavir to lamivudine in a total of 2,476 subjects.^121,^ ^122,^ ^124^–^126^ One included HBeAg-negative patients only,^121^ three enrolled treatment naïve,^121,^ ^122,^ ^126^ two included lamivudine resistant patients,^124,^ ^125^ and three reported baseline cirrhosis.^121,^ ^122,^ ^125^ Treatment duration lasted from 48–96 weeks and reported followup off therapy was 0–24 weeks. There were no significant differences in mortality at the end of treatment or after additional followup off treatment in any of the studies or in pooled analysis. However, only 0.5 percent of participants died (five in the entecavir group and eight in the lamivudine group), precluding accurate assessment of relative effectiveness of entecavir versus lamivudine on long-term mortality in these patients.

The remaining studies were small and short term. They assessed use of corticosteroids or different doses or duration of therapy. None demonstrated a mortality difference between treatment approaches. One small RCT from Egypt of 40 HBeAg-positive patients (40 percent with cirrhosis) found no difference in mortality after 16 weeks of interferon alfa-2b compared to placebo and 48–64 weeks of followup.^83^ Interferon alfa-2b with corticosteroid pretreatment compared to symptomatic therapy without antiviral drugs failed to reduce mortality in a small RCT of 20 HBeAg-positive South African patients.^70^ Steroid withdrawal and low dose of interferon alfa-2b for 24 weeks in 56 HBeAg-positive patients did not reduce mortality rates (ARD -0.11 95 percent CI -0.27; 0.06).^86^ Two RCTs^86,^ ^90^ of interferon alfa-2b did not find a dose- response effect on mortality among HBeAg-positive patients.^86,^ ^90^

Dose or duration of the therapy did not affect mortality. Prolongation of adefovir administration did not reduce mortality in 125 HBeAg-negative Greek patients.^111^ Entecavir in different doses did not decrease mortality in patients with lamivudine resistant hepatitis.^124^

In conclusion, antiviral medications did not reduce mortality versus placebo, compared to other antiviral medications, or in combination with corticosteroids regardless of HBeAg or cirrhosis status. Studies reporting mortality evaluated different patient populations and drug combinations, thus generally precluding pooling. Level of evidence and confidence in effect estimate is low. Studies assessing mortality had inadequate size and duration to detect significant differences.

Cirrhosis. Cirrhosis was assessed in two small relatively short-term studies of interferon alfa-2b (Appendix E Figure 4.) Compared to placebo, interferon alfa-2b at 16 weeks of therapy and at 48–64 weeks of followup did not reduce incident cirrhosis (1/20 versus 2/20; ARD -0.05, 95 percent CI -0.21; 0.11) in 40 HBeAg-positive patients (40 percent with baseline histologically confirmed cirrhosis).^83^ The study did not have power to detect differences in incident cirrhosis.^176^ The French Multicenter Group examined interferon alfa-2b alone and with simultaneous prednisone for 24 weeks and reported no significant difference (ARD -0.06, 95 percent CI -0.24; 0.11) in histologically confirmed cirrhosis at the end of therapy and at 24 weeks of followup (3/31 versus 4/25).^85^

In conclusion, sparse data suggest no effects of interferon alfa-2b alone or in combination with steroids on short-term incident cirrhosis. The long-term effects of interferon alfa-2b alone or in combination with steroids on clinical outcomes are unknown. No data were available for other antiviral drugs. Overall level of evidence and confidence in effect estimate is low.

Hepatic decompensation. Hepatic decompensation was reported in three studies;^122,^ ^126,^ ^141^ one small RCT compared lamivudine to placebo^141^ and two assessed outcomes after 52–96 weeks of entecavir versus lamivudine administration.^122,^ ^126^ Studies reported very few cases of hepatic decompensation. Eighty weeks of lamivudine treatment did not affect the development of hepatic decompensation in 74 Korean patients with lamivudine-resistant mutant CHB (ARD 0.05, 95 percent CI -0.11; 0.22).^141^ The Benefits of Entecavir for Hepatitis B Liver Disease (BEHoLD) study evaluated 715 HBeAg-positive patients of which 8 percent had cirrhosis at baseline.^122^ An American study^126^ also assessed 709 HBeAg-positive patients, though they did not report the number of subjects with cirrhosis at baseline. Neither found a difference in hepatic decompensation between entecavir compared to lamivudine.^122,^ ^126^ There were only two cases reported both in the lamivudine group.

In conclusion, there is insufficient evidence regarding the relative effects of entecavir versus lamivudine in preventing hepatic decompensation over 1–2 years among HBeAg-positive patients. Effects of other antiviral drugs or in different patient populations are unknown.

Hepatocellular carcinoma was reported in four studies. None demonstrated a statistically significant difference. Two studies compared placebo to lamivudine^132^ or interferon alfa-2b.^91^ One compared the addition of corticosteroids to interferon alfa-2b versus interferon monotherapy,^85^ and one examined the effects of prolonged adefovir therapy.^111^ Incidence of hepatocellular carcinoma did not differ between lamivudine (130 weeks, 17/436) and placebo (16/215) in a multicenter study of 651 Asian patients (58 percent HBeAg-positive) with confirmed cirrhosis (61 percent) or advanced fibrosis (ARD -0.04, 95 percent CI -0.07; 0.00).^132^ A further analysis that adjusted for country, sex, baseline ALT level, Child-Pugh score, and Ishak fibrosis score found a borderline significant effect (HR 0.49, 95 percent CI 0.25; 0.99, p=0.047 borderline significant).^132^

Interferon alfa-2b for 96 weeks compared to placebo failed to prevent hepatocellular carcinoma in 42 HBeAg-negative Italian patients.^91^

The French Multicenter Group did not find protective effects of adding corticosteroids to interferon alfa-2b compared to interferon alone at the end of 24 weeks of therapy and at 24 weeks of followup in treatment naïve HBeAg-positive patients with CHB (ARD -0.02, 95 percent CI -0.28; 0.24).^85^

In conclusion, study number, design, and duration were inadequate to accurately assess the impact of treatments on hepatocellular cancer. Limited low level evidence from one multinational RCT suggested that 130 weeks of lamivudine may reduce the incidence of hepatocellular carcinoma in Asian adults with hepatitis B and cirrhosis or advanced fibrosis. Results come from a single trial that noted no significant differences in crude rates and reported a nonstatistically significant increase in all-cause mortality with lamivudine. Protective effects on HCC with lamivudine were significant only after adjustment for baseline variables and after excluding five individuals who developed hepatocellular cancer within the first year of the study. Interferon alfa-2b monotherapy was not protective in a single small short-term study reporting very few events (low confidence). Addition of corticosteroids to alfa interferon was not superior to alfa interferon alone in a single, small short-term study with few events (low confidence). There are no data evaluating other antiviral agents.

Virological outcomes (Appendix E Tables 4 and 5). HBsAg clearance is one of the diagnostic criteria proposed to define complete response and resolved hepatitis B (the American Association for the Study of Liver Diseases).^1^ Other parameters include undetectable HBV DNA, normal ALT, and presence of antiHBsAg in patients with previous known history of acute or CHB (the American Association for the Study of Liver Diseases).^1^ HBsAg-positive patients can transmit infection to others. Therefore, sustained HBsAg clearance after drug administration benefits not only individual patients but prevents transmission of hepatitis B virus to others. Short-term effects reported in RCTs among patients “on treatment” might be generalizable to clinical settings if these treatments could be continued indefinitely. Six studies^10,^ ^67,^ ^70,^ ^83,^ ^84,^ ^91^ compared active drugs to placebo at the end of the treatments, ten studies^61,^ ^67,^ ^83,^ ^87,^ ^91,^ ^136,^ ^139^ evaluated sustained HBsAg clearance, and ten studies^67,^ ^69,^ ^71,^ ^84,^ ^99,^ ^111,^ ^119,^ ^122,^ ^126^ examined sustained comparative effectiveness between antiviral treatments on sustained HBsAg loss (Appendix E Table 5).

From six studies that compared active drugs with placebo or no treatment,^10,^ ^67,^ ^70,^ ^83,^ ^84,^ ^91^ only one RCT of 169 HBeAg-positive patients found a significant increase in HBsAg loss (ARD 0.12, 95 percent CI 0.02; 0.23) at the end of 24 weeks administration of interferon alfa-2b, 5MU/day^84^ (Appendix E Figure 5). The same study reported a similar significant increase in HBsAg loss after interferon alfa-2b with corticosteroid (ARD 0.11, 95 percent CI 0.02; 0.21). Pooled analysis of two RCTs that compared steroid pretreatment followed by interferon alfa-2b to no antiviral drugs found a significant increase in HBsAg loss at the end of the treatments (pooled ARD 0.11, 95 percent CI 0.02; 0.20).^70,^ ^84^

All treatments failed to increase rates of post-treatment HBsAg loss at followup off drug administration (range 8–48 weeks off drug) (Appendix E Figure 6).^61,^ ^67,^ ^83,^ ^87,^ ^91,^ ^136,^ ^139^

Comparative effectiveness of interferon and reverse transcriptase inhibitors on HBsAg loss at the end of the drug administration did not differ in any of the ten RCTs that examined the association.^67,^ ^69,^ ^71,^ ^84,^ ^99,^ ^111,^ ^119,^ ^122,^ ^126^

Entecavir and lamivudine resulted in similar rates of HBsAg loss and seroconversion.^122,^ ^126^ Combination of interferon alfa-2b with lamivudine did not increase HBsAg loss compared to lamivudine alone in HBeAg-positive^67^ and negative patients.^71^

Adefovir combined with lamivudine resulted in the same rates of HBsAg loss as adefovir or lamivudine monotherapy.^119^ Longer treatment with adefovir for 240 weeks resulted in worse rates of HBsAg clearance compared to 114 weeks (ARD -0.05, 95 percent CI -0.09; -0.01).^111^ (Appendix E Figure 7).

Comparative effectiveness of interferon and reverse transcriptase inhibitors on HBsAg loss or seroconversion to antiHBsAg at followup off the drug administration did not differ in any of the 12 RCTs that examined the association^63,^ ^66,^ ^67,^ ^74,^ ^76,^ ^80,^ ^85,^ ^88,^ ^90,^ ^98,^ ^99,^ ^109^ (Appendix E Figure 8). Duration of followup off treatment ranged from 16–48 weeks; therefore, outcomes at longer duration off treatment are not known. Four RCTs examined the effects of interferon alfa-2b on HBsAg loss combined with other criteria of resolved hepatitis B including loss of HBV DNA and HBeAg and normalization of ALT^73,^ ^82,^ ^89,^ ^91^ (Appendix E Figure 9). Trials included patients who were HBeAg-positive (N=113),^73^ HBeAg-negative (N=42),^91^ or both positive and negative for HBeAg (N=58).^82,^ ^89^ The proportion of patients with baseline cirrhosis varied from 5 percent^82^ to 17 percent.^91^ Interferon alone and with corticosteroid pretreatment failed to increase rates of resolution of hepatitis B as assessed by the combined outcomes of HBV DNA, HBeAg, and HBsAg clearance and normalization of ALT levels.

In conclusion, interferon alfa-2b alone and with steroid pretreatment increased HBsAg loss by about 10–15 percent at the end of drug administration (moderate level of evidence). However, sustained effects of interferon alfa-2b on HBsAg loss beyond 48 weeks off treatment have not been examined. Additionally, interferon alfa-2b failed to increase rates of several criteria of resolved hepatitis B. The effects of other drugs and their combinations on composite criteria of resolved hepatitis B including HBsAg loss have not been investigated. Comparative effectiveness of evaluated active treatments on short-term intermediate outcomes (loss of HBsAg) was similar at the end of the therapy and at short-mid duration followup off treatment in the populations studied (moderate evidence).

HBV DNA clearance (Appendix E Tables 4 and 5) is associated with a favorable prognosis, though little longitudinal data is available in persons with HBV DNA levels.^1,^ ^5^ Undetectable levels of HBV DNA in combination with HBeAg and HBsAg loss determine resolved hepatitis. A value of 20,000 IU/mL is an arbitrary threshold defining active hepatitis or inactive HBsAg carrier state.^1^

Studies obtained assays with different sensitivity to detect HBV DNA. Viral load was measured using polymerase chain reaction assay,^63,^ ^74,^ ^87,^ ^90,^ ^110,^ ^113,^ ^117,^ ^119^–^123,^ ^126,^ ^127,^ ^129,^ ^139,^ ^143^ reverse transcription polymerase chain reaction assay,^107,^ ^124^ or solution hybridization assay.^62,^ ^66^–^69,^ ^71,^ ^72,^ ^75,^ ^77,^ ^84^–^86,^ ^136,^ ^145^ Obtained assay methods had different detection limits and units to measure viral load: <200 copies/mL,^117^ <300 copies/mL,^113,^ ^121,^ ^122,^ ^126^ <400 copies/mL,^96,^ ^102,^ ^116^ <500 copies/mL,^117^ <1,000 log copies/ml,^10,^ ^111^ <3 log10 copies/mL,^143^ <1.6pg/mL,^131,^ ^140^ <2.5 pg/mL,^142^ <3 pg/mL,^62,^ ^67^ or <6pg/mL.^77^ We explored heterogeneity in drug effects across the studies using the assay to measure HBV DNA loss and did not convert units of cut offs.

We reviewed 43 studies that examined HBV DNA clearance after interferon and reverse transcriptase inhibitors.^10,^ ^57,^ ^62,^ ^63,^ ^66^–^69,^ ^71,^ ^72,^ ^75,^ ^77,^ ^80,^ ^85^–^88,^ ^90,^ ^92,^ ^96,^ ^106,^ ^107,^ ^110^–^113,^ ^117,^ ^119^–^124,^ ^126,^ ^127,^ ^129,^ ^131,^ ^133,^ ^136,^ ^137,^ ^139,^ ^142,^ ^145^ Twenty-eight publications included HBeAg-positive.^63,^ ^65,^ ^68,^ ^69,^ ^72,^ ^75,^ ^77,^ ^80,^ ^84^–^88,^ ^90,^ ^92,^ ^96,^ ^102,^ ^106,^ ^107,^ ^112,^ ^119,^ ^120,^ ^126,^ ^127,^ ^129,^ ^131,^ ^136,^ ^140^ Five reports assessed HBeAg-negative patients;^10,^ ^71,^ ^74,^ ^110,^ ^111^ the rest of the studies included patients with chronic active hepatitis B independent of HBeAg baseline status. Twenty trials examined the effects of interferon alfa-2b,^62,^ ^63,^ ^65^–^69,^ ^71,^ ^72,^ ^74,^ ^75,^ ^77,^ ^80,^ ^84^–^88,^ ^90,^ ^92^ one trial examined peginterferon alfa-2a,^96^ eight publications reported HBV DNA loss after adefovir,^10,^ ^110^–^113,^ ^117,^ ^119,^ ^120^ five articles^121^–^124,^ ^126^ examined the effects of entecavir on HBV DNA clearance, and 39 analyzed the effects of lamivudine.^57,^ ^62,^ ^63,^ ^67,^ ^68,^ ^71,^ ^72,^ ^74,^ ^75,^ ^77,^ ^96,^ ^102,^ ^106,^ ^107,^ ^119,^ ^121^–^124,^ ^126,^ ^127,^ ^129,^ ^131,^ ^133,^ ^136,^ ^137,^ ^139,^ ^140,^ ^142,^ ^143,^ ^145^

Effects of drugs on HBV DNA clearance at the end of the treatment. Adefovir administration for 48–96 weeks increased rates of HBV DNA loss compared to placebo at the end of treatment in four reports^10,^ ^110,^ ^112,^ ^113^ with a consistent across-the-studies increase in relative risk (pooled RR 20.41, 95 percent CI 6.79; 61.32). The pooled absolute risk difference was significant (pooled ARD 0.38, 95 percent CI 0.23; 0.53) but there was evidence of statistical heterogeneity between studies that could not be explained by control rate of HBV DNA clearance, length of treatments, or baseline HBeAg status (metaregression p value >0.05) (Appendix E Figure 10).

Interferon alfa-2b for 16 weeks compared to no antiviral treatment ^69^ (ARD 0.45, 95 percent CI 0.22; 0.68) increased HBV DNA loss in HBeAg-positive patients. The same RCT of HBeAg-positive patients reported a significant increase in HBV DNA loss after 16 weeks of interferon alfa-2b combined with corticosteroid (ARD 0.25, 95 percent CI 0.04; 0.46).^69^

Lamivudine for 12–104 weeks compared to placebo or usual care^67,^ ^129,^ ^131,^ ^133,^ ^136,^ ^139,^ ^145^ increased HBV DNA clearance with consistent across-the-studies relative risk (pooled RR 3.79, 95 percent CI 2.71; 5.30). The pooled absolute risk difference was significant (pooled ARD 0.48, 95 percent CI 0.31; 0.66), but inconsistent, with evidence of statistical heterogeneity that could not be explained by length of treatment or control rate of HBV DNA loss (metaregression p value >0.05). The effects of baseline HBeAg status, assay to measure viral load, or the proportion of patients with baseline cirrhosis, could not explain variability in the results. A valid metaregression was not possible because not all studies reported this information.

Interferon alfa-2b combined with lamivudine for 52 weeks compared to placebo^67^ increased the rate of undetectable HBV DNA (<3pg/mL—a measure used to define resolved hepatitis B) (ARD 0.48, 95 percent CI 0.33; 0.63) with random differences (ARD 0.05, 95 percent CI -0.09; 0.18) in sustained HBV DNA response (no two consecutive detectable HBV DNA on treatment) in predominantly HBeAg-positive patients (98 percent).

Comparative effects of antiviral drugs of HBV DNA clearance at the end of treatment was mixed across RCTs (Table 5). Entecavir demonstrated greater HBV DNA clearance compared to lamivudine;^121^–^123,^ ^126^ however, the effect was not consistent across studies in either multiplicative scale (pooled RR 1.64, 95 percent CI 1.22; 2.22) or absolute risk differences (0.23, 95 percent CI 0.11; 0.35). Rates in the control group and the dose of entecavir could not explain heterogeneity across the studies. Pooled analysis suggested that effects in HBV DNA clearance became significant after more than 1 year of treatment (ARD 0.30, 95 percent CI 0.16; 0.44 at >1 year of active treatment) with no significant differences at 6 months of active treatment (ARD 0.09, 95 percent CI -0.04; 0.21; metaregression p-value 0.04).

Table 5 Absolute risk difference in tested nonclinical outcomes after antiviral drugs for chronic hepatitis B in adults

Comparison | HBsAg [RCTs/Patients] | HBeAg [RCTs/Patients] | HBV DNA Clearance [RCTs/Patients] | Histology Improved [RCTs/Patients] | ALT Normal [RCTs/Patients] | Relapse/Mutation [RCTs/Patients]
Adefovir vs. placebo | SC: NS [1/120] L | Loss: 0.11 (0.06; 0.16) [2/995] M SC: 0.05 (0.01; 0.09) [2/700] H | 0.38 (0.23; 0.53) [4/1002] H 20.41 (6.79; 61.32) [4/1002] 0.59 (0.46; 0.72)* [1/120] L | Fibrosis: 0.20 (0.14; 0.26) [2/699] M Necroinflammation scores: 0.26 (0.17; 0.34) [3/819] H | 0.40 (0.30; 0.49) [5/1342] 2.97 (2.38; 3.69) H 0.26 (0.19; 0.33)* [2/600] M | NS [2/1055] L NS* [1/140] L
LAM vs. placebo | Loss: NS [1/175] L NS* [3/1068] L | Loss:0.13 (0.04; 0.22) [4/1349] M 0.15 (0.05; 0.24)* [2/318] M SC: 0.05 (0.001; 0.10) [6/1638] H 1.70 (1.05; 2.74) NS * [2/318] L | 0.48 (0.31; 0.66) [7/1305] 3.79 (2.71; 5.30) H 0.08 (0.00; 0.15)* [1/136] L | Necroinflammation: 2.09 (1.60; 2.74) M 0.25 (0.13; 0.38) [4/580] M | 0.22 (0.13; 0.31) [7/1602] 2.42 (1.94; 3.01) M 0.21 (0.04; 0.38)* [1/136] L | YMDD mutation: 0.43 (0.38; 0.48) [2/826] H
Adefovir + LAM vs. LAM | Loss: NS [1/39] L | Loss: 0.12 (0.03; 0.21) [2/134] M SC: NS [2/134] L | 0.25 (0.10; 0.39) [2/134] L | | 0.32 (0.13; 0.52) [2/13] M | YMDD:-0.33 (-0.50; -0.17) [1/95] L Wild type mutation: NS [1/95] L
Adefovir+ LAM vs. adefovir | Loss: NS [1/39] L | Loss: NS [1/39] L SC: NS[1/39] L | NS:[1/39] L | | NS [1/39] L
Entecavir vs. LAM | Loss: NS [2/1117] M SC: NS [1/408] L | Loss: NS [3/1112] L SC: NS [3/1185] M | 0.23 (0.11; 0.35) [4/1636] 1.64 (1.22; 2.22) L/M NS*1/709] L | Necroinflammation: 0.14 (0.04; 0.24) [3/1633] M Fibrosis: NS [2/995] M | 0.22 (0.11; 0.32) [6/2423] 1.62 (1.28; 2.06) H | NS [0/1347] L -0.16 (-0.20; -0.12)* [1/709] L
LAM vs. adefovir | | Loss: NS [1/38] L SC:NS [1/38] L | -0.26 (-0.47; -0.06) [1/38] L | | -0.42 (-0.67; -0.18) [1/38] L
LAM vs. telbivudine | | Loss: NS [1/63] L SC: NS [1/63] L | -0.30 (-0.55; -0.04) [1/63] L | | NS [1/85] L | NS [1/63] L
Telbivudine vs. adefovir | | Loss: NS [1/135] L SC: 6.03 (2.20; 16.52) [1/136] L | 0.28 (0.12; 0.44) [1/136] L | | NS [1/135] L
Telbivudine+LAM vs. LAM | | Loss: NS[1/60] L SC: NS [1/60] L | NS [1/60] L | | NS [1/101] L | NS [1/60] L
Telbivudine+LAM vs. telbivudine | | Loss: NS [1/85] L SC: NS [1/85] L | NS [1/85] L | | NS [1/101] L | NS [1/85] L
Interferon alfa-2b vs. placebo | Loss: NS [3/166] M NS* [4/247] L SC: NS* [2/82] L | Loss: 0.55 (0.29; 0.81) [1/40] L 2.52 (1.55; 4.10) 0.28 (0.07; 0.50)* [3/351] M SC:NS [1/40] L 0.12 (0.03; 0.21) * [2/304] M | 0.45 (0.22; 0.68) [1/34] L 0.44 (0.27; 0.60)* [3/168] L | Total scores: NS* [1/40] L HAI scores:0.24 (0.00; 0.48) [1/72] L | 0.31 (0.17; 0.44)* [2/131] M | Relapse: NS* [5/378] H
Interferon alfa-2b+lamivudine vs. placebo | Loss: 0.06 (0.00; 0.13) [1/119] L NS* [1/119] L | Loss: NS [1/118] L NS* [2/450] M SC: NS [1/119] L NS* [2/450] L | 0.48 (0.33; 0.63) [1/119] L NS* [1/119] L | HAI scores NS [1/119] L | NS [1/119] L | YMDD mutation NS [1/118] L
Interferon alfa-2b+ corticosteroid vs. no treatment | Loss: 0.11 (0.02; 0.20) [2/103] M | | 0.25 (0.04; 0.46) [1/34] L NS* [2/121] M | | 0.25 (0.06; 0.43)* [1/87] L | Relapse NS* [1/87] L
Interferon alfa-2b vs. LAM | | Loss: NS [1/151] L NS* [2/625] M SC: NS[1/151] L NS* [3/776] M | NS [1/76] L NS* [1/151] L | Knodell scores: NS* [1/151] L | NS [1/151] L NS* [2/151] L | YMDD mutation -0.23 (-0.33; -0.14)* [1/151] L
Interferon Alfa 2b+ LAM vs. interferon alfa-2b | | Loss: NS [1/144] L NS* [2/347] M SC: NS [1/144] L NS* [3/482] L | NS [1/144] L NS* [2/278] L | HAI scores 0.54 (0.28; 0.79) [1/48] L Knodell scores NS* [1/144] L | NS [1/144] L NS* [2/192] L | YMDD mutation NS* [1/144] L
Interferon alfa-2b+ LAM vs. LAM | Loss: NS [2/262] L NS* [3/495] L | Loss: NS [3/414] M NS* [5/1167] M SC: NS [4/565] H NS* [3/490] M | NS [7/786] H NS* [4/365] M | HAI scores NS [3/327] M necroinflammation NS [2/389] L Knodell scores NS* [1/157] L | NS [5/626] M NS* [6/751] M | Relapse: NS [4/326] H NS* [2/158] L YMDD mutation: -0.18 (-0.35; -0.01) [6/721] M 0.42 (0.16; 1.09) M -0.23 (-0.32; -0.14)* [1/157] L
Interferon alfa-2b+ corticosteroid vs. IFN alfa-2b | Loss: NS [2/125] M NS* [3/141] L | Loss: NS [2/77] L NS* [3/122] L SC: NS* [2/85] L | NS [2/77] L NS* [6/322] H | | NS* [3/170] M | Relapse: NS* [2/141] L
Peginterferon alfa-2a vs. LAM | | Loss: 0.08 (0.01; 0.16) M 0.13 (0.05; 0.20)* [1/543] M SC: NS [1/543] L 0.13 (0.06; 0.20) [1/814]* M | -0.15 (-0.22; -0.07) [1/543] M 0.09 (0.04; 0.14) [1/543]* L | Necroinflammation 0.12 (0.02; 0.22) [1/552]* L Fibrosis: NS* [1/552] L HAI: NS [2/1366]* M | -0.29 (-0.42; -0.17) [2/905] 0.57 (0.46; 0.70) [2/905] M 0.13 (0.07; 0.20)* [2/905] H | YMDD mutation -0.25 (-0.31; -0.20) [1/543] L
Peginterferon alfa-2a+LAM vs. LAM | | Loss: NS [1/543] L 0.07 (0.00; 0.15)* [1/543] M SC: NS [1/543] L 0.08 (0.01; 0.15) *[1/814] L | 0.29 (0.21; 0.37) [1/543] M 0.09 (0.04; 0.13) [1/543]* L | Total scores: NS [2/1366]* H | -0.20 (-0.29; -0.10) [2/905] H 0.13 (0.06; 0.19) [2/905]* H | YMDD mutation -0.22 (-0.28; -0.16) [1/543] L
Peginterferon alfa-2a+LAM vs. peginterferon alfa-2a | | Loss: NS [1/542] L NS [1/542]* M SC: NS [1/542] L NS [1/814]* L | 0.44 (0.36; 0.51) [1/542] M NS[1/542]* L | Total scores: NS [1/96]* L | NS [1/542] L NS [1/542]* L | YMDD mutation: 0.03 (0.01; 0.06) [1/542] L
Peginterferon alfa-2b vs. interferon alfa-2b | SC: NS* [1/230] | Loss: 0.10 (0.00; 0.21) [1/230]* L | | | NS [1/230]* L
Peginterferon alfa-2b+LAM vs. LAM | Negative HBVDNA+ HBsAg SC 0.32 (0.14; 0.50) [1/100] | Loss: 0.34 (0.16; 0.52) [1/100] M SC: 0.32 (0.14; 0.50) [1/100] L NS: [1/100]* L | NS [1/100] L NS [1/100]* L | HAI scores NS: [1/100] L | NS [1/100] L | NS: [1/100]* L YMDD mutation: NS [1/100] L
Peginterferon alfa-2b+LAM vs. peginterferon alfa-2b | Loss: NS [1/307] | Loss: 0.12 (0.01; 0.22) [1/307] M NS [2/614]* M SC: NS [1/307]L NS: [1/307]* L | | fibrosis scores: NS [1/307]* L necroinflammation scores: NS [1/307] L | 0.14 (0.03; 0.24) [1/307] L NS [1/307]* L | YMDD mutation: 0.09 (0.04; 0.14) [1/307] L

SC = seroconversion; NS = not significant; italic = relative risk; *= outcomes off treatments; LAM = lamivudine Level of evidence: L = low; M = moderate; H = high

Telbivudine resulted in greater rates of HBV DNA loss compared to adefovir at 24 (ARD 0.28, 95 percent CI 0.12; 0.44) but not 52 weeks of treatment^120^ in a multinational study of 135 HBeAg-positive, naïve to antiviral drugs patients. Only one drug demonstrated a significant dose response increase in rates of HBV DNA loss, 100–300 mg of lamivudine resulted in greater viral clearance compared to 25–100 mg (pooled ARD 0.21, 95 percent CI 0.10; 0.31).^133,^ ^137,^ ^145^ The length of treatment was not associated with greater response increase in HBV DNA loss.^131^ Larger doses or duration of administration of adefovir did not result in larger viral clearance.^10,^ ^111^–^113,^ ^120^ Only one RCT of adefovir (Adefovir Dipivoxil 437 Study Group) reported greater HBV DNA loss after 30 versus 10 mg (ARD 0.18, 95 percent CI 0.08; 0.27).^112^ Entecavir did not show a dose response association with HBV DNA loss in a single 24-week, double-blind, multicenter, phase II clinical trial.^123^ Limited evidence suggested that lamivudine was less effective than adefovir (ARD -0.26, 95 percent CI -0.47; -0.06) in patients with lamivudine-resistant CHB^119^ and less effective than telbivudine in HBeAg-positive patients with compensated (upper limit of normal for serum ALT was 48 U/L for men and 37 U/L for women) CHB (ARD -0.30, 95 percent CI -0.55; -0.04).^127^

Combined therapy of adefovir with lamivudine resulted in increased HBV DNA clearance compared to lamivudine alone^117,^ ^119^ (pooled ARD 0.25, 95 percent CI 0.10; 0.39) but not compared to adefovir alone.^119^ Interferon alfa-2b combined with lamivudine resulted in the same HBV DNA loss when compared to interferon alfa-2b alone.^62^ Longer administration of interferon alfa-2b + lamivudine for 20 weeks did not increase HBV DNA loss compared to pretreatment with interferon alfa-2b followed by lamivudine.^92^ Combined interferon alfa-2b with lamivudine therapy failed to increase viral clearance compared to lamivudine alone (pooled ARD 0.03, 95 percent CI -0.11; 0.17).^62,^ ^63,^ ^67,^ ^71,^ ^74,^ ^75,^ ^77^ Comparative effects of other antiviral drugs was similar at the end of the treatment (Appendix E Table 5).

Effects of drugs on HBV DNA clearance at followup off treatment (Table 5). Limited evidence suggests that antiviral drugs and their combinations sustain HBV DNA clearance at followup off therapy ranging from 18–24 weeks (Appendix E Figure 11). Interferon alfa-2b at 8–24 weeks of followup increased HBV DNA loss compared to placebo or no antiviral therapy (pooled ARD 0.44, 95 percent CI 0.27; 0.60);^69,^ ^87^ however, the effects were attenuated at longer followup at 48 weeks off the therapy (pooled ARD of three studies 0.28, 95 percent CI -0.04; 0.60)^69,^ ^84,^ ^87^ (Appendix E Table 5). Limited evidence from one RCT suggests sustained effects of lamivudine on HBV DNA loss at 24 weeks of followup after 96 weeks of drug administration (ARD 0.08, 95 percent CI 0.01; 0.15).^139^ One large RCT, reported a significant benefit from adefovir administration in HBeAg-negative patients that was sustained at 18 weeks off treatment (ARD 0.59, 95 percent CI 0.46; 0.72).^10^ Entecavir provided similar HBV DNA loss compared to lamivudine at 24 weeks of followup.^122^ Sustained effects of the drugs that demonstrated significant difference at the end of the treatment have not been investigated or were not significant (Appendix E Table 5).

In conclusion, lamivudine and adefovir resulted in HBV DNA clearance that was large in magnitude and maintained for periods up to 24 weeks after the treatment in patients with CHB (moderate to high evidence). Interferon alfa-2b resulted in off treatment HBV DNA loss for 8–24 weeks, the effect was attenuated at longer followup off the treatment (low evidence). Entecavir and adefovir were more effective than lamivudine at the end of the treatment (low). However, sustained differences off the treatments were not significant (entecavir) or have not been examined in RCTs. HBV DNA clearance was greater after combined therapy of adefovir and lamivudine compared to lamivudine alone at the end of the treatment (low to moderate). Long-term sustained effect off therapies has not been examined.

Effects of drugs on HBeAg clearance at the end of treatment (Table 5 and Appendix E Tables 4 and 5). Thirty-five included studies reported HBeAg loss at the end of antiviral drug treatment in patients with positive baseline HBeAg status.^57,^ ^61,^ ^62,^ ^64,^ ^66,^ ^67,^ ^69,^ ^72,^ ^75,^ ^80,^ ^83,^ ^86^–^88,^ ^92,^ ^94,^ ^96,^ ^98,^ ^99,^ ^102,^ ^106,^ ^109,^ ^112,^ ^113,^ ^117,^ ^119,^ ^120,^ ^122^–^125,^ ^127,^ ^136,^ ^140,^ ^143^ Limited evidence from one small RCT^83^ suggested that interferon alfa-2b increased HBeAg loss compared to no antiviral treatments (ARD 0.55, 95 percent CI 0.29; 0.81) Lamivudine for 52 weeks compared to placebo increased HBeAg loss in three of four RCTs (pooled ARD 0.13, 95 percent CI 0.04; 0.22), but the effect size was not consistent across the studies.^64,^ ^67,^ ^136,^ ^140^ (Appendix E Figure 12). One short-term RCT of 122 Chinese patients found random changes in HBeAg loss after 12 weeks of drug administration.^140^ Adefovir for 48–52 weeks compared to placebo resulted in increased rates of HBeAg loss (pooled ARD 0.11, 95 percent CI 0.06; 0.16).^112,^ ^113^ Neither dose^112^ nor duration of treatment of adefovir increased HBeAg loss.^113^ No differences in HBeAg clearance were reported after three doses of entecavir (0.01; 0.1; or 0.5 g) administered for 24 weeks.^123^ Longer treatment duration with interferon alfa-2b did not have any effect on HBeAg loss.^66^

Comparative effects of monotherapies was significant only for peginterferon alfa-2a when compared to lamivudine in one large RCT of 814 patients (Peginterferon Alfa-2a HBeAg-Positive Chronic Hepatitis B Study Group, ARD 0.08, 95 percent CI 0.01; 0.16).^96^ Adefovir followed by telbivudine resulted in the same rates of HBeAg loss compared to adefovir alone.^120^ Entecavir did not increase HBeAg loss compared to lamivudine^122,^ ^123,^ ^125^ at the end of 24–63 weeks of therapy. Comparative effects of evaluated combined therapies was similar (Appendix E Table 5). Adefovir combined with lamivudine for 48–52 weeks increased HBeAg loss compared to lamivudine alone in two RCTs (pooled ARD 0.12, 95 percent CI 0.03; 0.21).^117,^ ^119^

Effects of drugs on HBeAg clearance at followup off the treatment (Table 5). Significant HBeAg clearance at followup off treatments was demonstrated for interferon alfa-2b (pooled RR 2.52, 95 percent CI 1.55; 4.1)^64,^ ^83,^ ^87^ (Appendix E Figure 13). An increase in absolute risk of HBeAg loss was significant (pooled ARD 0.28, 95 percent CI 0.07; 0.50) but not consistent across RCTs. In patients receiving 52 weeks of lamivudine, HBeAg loss was greater at 16 weeks off therapy than patients receiving placebo (pooled ARD 0.15, 95 percent CI 0.05; 0.24).^67,^ ^136^ HBeAg loss at 24 weeks off treatment was greater after peginterferon alfa-2a compared to lamivudine therapy in one large RCT (ARD 0.13, 95 percent CI 0.05; 0.20).^96^ However, this study did not find a significant difference in HBeAg clearance after combination of peginterferon alfa-2a with lamivudine when compared to peginterferon alfa-2a alone or lamivudine alone. The HBeAg loss did not demonstrate a dose response association with peginterferon alfa-2a at followup.^94^ Interferon alfa-2b combined with corticosteroid compared to interferon alfa-2b alone,^80,^ ^86,^ ^88^ interferon alfa-2b combined with lamivudine compared to placebo,^64,^ ^67^ interferon alfa-2b alone,^62,^ ^64^ or lamivudine alone^62,^ ^64,^ ^67,^ ^72,^ ^75^ did not result in greater off treatment HBeAg clearance. Interferon alfa-2b and lamivudine provided similar off-treatment HBeAg loss.^62,^ ^64^

Effects of drugs on HBeAg seroconversion at the end of treatment (Table 5). HBeAg seroconversion was reported in 36 studies.^10,^ ^57,^ ^62^–^64,^ ^66^–^68,^ ^75,^ ^80,^ ^83,^ ^88,^ ^91,^ ^94,^ ^96,^ ^99,^ ^106,^ ^109,^ ^111^–^113,^ ^117,^ ^119,^ ^120,^ ^122^–^127,^ ^133,^ ^136,^ ^140,^ ^141,^ ^143,^ ^145^ At the end of the treatments, lamivudine increased HBeAg seroconversion with consistent results across the studies (pooled RR 1.69, 95 percent CI 1.05; 2.74)^64,^ ^67,^ ^136,^ ^140,^ ^141,^ ^145^ (Appendix E Figure 13); however, the effect size was not consistent (i.e., significant heterogeneity in effects across studies) in absolute risk scale (pooled ARD 0.05, 95 percent CI 0.01; 0.1, heterogeneity p value <0.05). The rate in the placebo group and duration of treatments could not explain the heterogeneity in absolute rates. Adefovir for 48–52 weeks compared to placebo resulted in increased rates of HBeAg seroconversion without dose response association (ARD 0.05, 95 percent CI 0.01; 0.09)^112,^ ^113^ (Appendix E Figure 14).

Effects of drugs on HBeAg seroconversion at followup off the treatment (Table 5). Interferon alfa-2b^64,^ ^83^ increased rates of HBeAg seroconversion versus placebo at 28–64 weeks of followup (ARD 0.12, 95 percent CI 0.03; 0.21). Lamivudine monotherapy failed to maintain HBeAg seroconversion at 16 weeks of followup.^67,^ ^136^ Interferon alfa-2b combined with lamivudine demonstrated inconsistent effects on HBeAg seroconversion at 6–28 weeks of followup.^64,^ ^67^ Pooled analysis of individual patient data from four RCTs found a significant increase in HBeAg seroconversion after combined therapy with interferon alfa-2b and lamivudine. (0.13, 95 percent CI 0.05; 0.21).^64^ Interferon alfa-2b combined with lamivudine did not result in better sustained HBeAg seroconversion compared to interferon alfa-2b alone.^62,^ ^64,^ ^68^ Limited evidence from one RCT of HBeAg-positive untreated patients suggested an increase in HBeAg seroconversion at 56 weeks off therapy (ARD 0.31, 95 percent CI 0.1; 0.63).^68^ Telbivudine compared to adefovir for 24–52 weeks increased HBeAg seroconversion in relative terms (RR 6.03, 95 percent CI 2.20; 16.52) but had random differences in absolute rates.^120^ Peginterferon alfa-2a increased HBeAg seroconversion at 24 weeks of followup compared to lamivudine (ARD 0.13, 95 percent CI 0.06; 0.20).^96^ Peginterferon alfa-2a combined with lamivudine resulted in greater HBeAg seroconversion compared to lamivudine alone (ARD 0.08, 95 percent CI 0.01; 0.15) but not peginterferon alfa-2a alone (ARD-0.05, 95 percent CI -0.12; 0.03).^96^ Combined treatments of peginterferon alfa-2b with for 60 weeks increased HBeAg seroconversion compared to lamivudine alone (ARD 0.32, 95 percent CI 0.14; 0.50).^106^ All other comparisons demonstrated random differences between compared treatments.

In conclusion, monotherapy with interferon alfa-2b and peginterferon alfa-2a increased off treatment HBeAg loss and seroconversion compared to placebo (moderate evidence and confidence). Lamivudine monotherapy increased rates of HBeAg loss at the end of the treatments and at followup (moderate to high) but did not maintain sustained HBeAg seroconversion (low). Limited low level evidence suggested that peginterferon alfa-2a increased HBeAg loss and seroconversion at followup. Combined therapy with lamivudine was more effective than lamivudine alone (low level of evidence and confidence).

Combined virologic and biochemical outcomes including HBV DNA loss, HBeAg clearance and seroconversion, and ALT normalization (Appendix E Table 4) were investigated in eight RCTs at the end of treatment^75,^ ^81,^ ^84,^ ^91,^ ^122,^ ^126,^ ^127,^ ^139^ and in 13 RCTs at followup off treatment^61,^ ^73,^ ^75,^ ^81,^ ^82,^ ^85,^ ^87,^ ^89,^ ^91,^ ^106,^ ^122,^ ^125,^ ^139^ (Table 4).

Table 4 Effects of drug therapies for chronic hepatitis B on combined outcomes

Active Treatments vs. Control Treatment | Treatment Duration/Followup Off Therapy, Weeks | Studies/Subjects Enrolled | Estimates (95% CI) *Dose Response Heterogeneity: p Value/I Squared, % | Level of Evidence/Comments
Combined outcomes (virological, histological, biochemical) at end of treatment
Interferon alfa 2b+ prednisone vs. no treatment^84^ | 24/0 | 1/87 | 0.29 (0.13; 0.46) (RD) | Low. Interferon alfa 2b+ prednisone vs. no treatment increased rates of negative HBV DNA and HBeAg
Interferon alfa-2b vs. no treatment^84^ | 24/0 | 1/84 | 0.30 (0.13; 0.46) (RD 35MU/week) 0.10 (-0.04; 0.24) (RD 7MU/week) | Low. Interferon alfa-2b vs. no treatment increased rates of negative HBV DNA and HBeAg after 35 but not 7 MU/week
Lamivudine vs. placebo^139^ | 96/0 | 1/136 | 0.46 (0.32; 0.59) (RD) | Low. Lamivudine vs. placebo increased rates of negative HBV DNA, normal ALT
Interferon alfa-2b vs. no treatment^81,91^ | 16–96/0 | 2/92 | 0.36 (0.20; 0.51) (RD) 0.473/0% | Low. Interferon alfa-2b vs. no treatment increased rates of negative HBV DNA and normal ALT
Entecavir vs. lamivudine^126^ | 52–96/0 | 2/1418 | 0.03 (-0.01; 0.08) (RD) 0.49/0% | Moderate. No differences between entecavir vs. lamivudine on negative HBV DNA and HBeAg
Interferon alfa-2b +lamivudine vs. lamivudine^75^ | 52/0 | 1/75 | 0.13 (-0.05; 0.31) (RD) | Low. No differences between interferon alfa-2b +lamivudine vs. lamivudine alone on loss of HBV DNA+HBeAg seroconversion+HBeAg loss
Lamivudine vs. telbivudine^127^ | 52/0 | 1/63 | -0.06 (-0.30; 0.19) (RD) | Low. No differences between lamivudine vs. telbivudine on loss of HBV DNA+HBeAg loss
Peginterferon alfa-2b+lamivudine vs. lamivudine^107^ | 60/0 | 1/100 | 0.32 (0.14; 0.50) (RD) | Low. Peginterferon alfa-2b+lamivudine vs. lamivudine increased rate of loss of HBV DNA+HBsAg seroconversion
Telbivudine+lamivudine vs. lamivudine^127^ | 52/0 | 1/60 | -0.07 (-0.30; 0.16) (RD) | Low. No differences between telbivudine+lamivudine vs. lamivudine alone on loss of HBV DNA and HBeAg
Telbivudine+lamivudine vs. telbivudine^127^ | 52/0 | 1/85 | -0.12 (-0.31; 0.06) (RD) | Low. No differences between telbivudine+lamivudine vs. telbivudine on loss of HBVDNA and HBeAg
Entecavir vs. lamivudine^122,126^ | 52–96 | 2/1418 | 0.03 (-0.01; 0.08) (RD) 0.49/0% | High. No differences between entecavir vs. lamivudine on negative HBV DNA and HBeAg
Interferon alfa 2b, 5MU/day vs. interferon alfa 2b, 1MU/day^84^ | 24/0 | 1/82 | 0.20 (0.01; 0.38) (RD)* | Low. Interferon alfa-2b in dose 35MU/week increased HBV DNA and HBeAg loss compared to 7MU/week
Interferon alfa 2b+lamivudine vs. lamivudine, 100^75^ | 52/0 | 1/75 | 0.13 (-0.05; 0.31) (RD) | Low. No differences between interferon alfa-2b+lamivudine vs. lamivudine on loss of HBV DNA+HBeAg seroconversion+HBeAg loss
Interferon alfa 2b, 5MU/day+ prednisolone. interferon alfa 2b, 1MU/day^84^ | 24/0 | 1/85 | 0.19 (0.01; 0.38) (RD) | Low. Interferon alfa 2b, 35MU/week+pretreatment with prednisone vs. interferon alfa-2b alone, 7MU/ week increased rate of loss of HBV DNA+HBeAg loss
Lamivudine vs. telbivudine^127^ | 52/0 | 1/63 | -0.06 (-0.30; 0.19) (RD) | Low. No differences between lamivudine vs. telbivudine on loss of HBV DNA+HBeAg loss
Peginterferon alfa-2b + lamivudine, vs. lamivudine^107^ | 60/0 | 1/100 | 0.32 (0.14; 0.50) (RD) | Low. Peginterferon alfa-2b+lamivudine vs. lamivudine increased rate of loss of HBV DNA+HBsAg seroconversion
Telbivudine+lamivudine vs. lamivudine^127^ | 52/0 | 1/60 | -0.07 (-0.30; 0.16) (RD) | Low. No differences between telbivudine +lamivudine vs. lamivudine on loss of HBV DNA and HBeAg
Telbivudine+lamivudine vs. telbivudine^127^ | 52/0 | 1/85 | -0.12 (-0.31; 0.06) (RD) | Low. No differences between telbivudine+lamivudine vs. telbivudine on loss of HBV DNA and HBeAg
Combined outcomes (virological, histological, biochemical) end of followup
Interferon alfa 2b+prednisone vs. no treatment^73^ | 24/24 | 1/76 | 0.00 (-0.05; 0.05) (RD) | Low. Sparse data (0 events). Interferon alfa 2b+prednisone compared to no treatment did not increase HBV DNA, HBsAg, and HBeAg loss
Interferon alfa-2b vs. no treatment^61,^,^73,^,^87,91^ | 16–96/24–144 | 4/282 | 0.22 (0.08; 0.36) (RD) 0.042/63.4% | Moderate. Interferon alfa-2b vs. no treatment increased rates of negative HBV DNA+HBeAg with consistent results in multiplicative scale
2.96 (1.40; 6.25) (RR) 0.313/16% | Control rate or duration of treatment and followup could not explain statistical heterogeneity in absolute rate
Lamivudine vs. placebo^139^ | 96/24 | 1/136 | 0.07 (-0.08; 0.21) (RD) | Low. Lamivudine vs. placebo did not increase loss of HBV DNA and HBeAg at time of followup
Interferon alfa-2b vs. no treatment^82,89^ | 16–96/24–48 | 2/116 | 0.03 (-0.03; 0.10) (RD) 1/0% | Moderate. Interferon alfa-2b did not increase rate of negative HBV DNA, normal ALT, HBsAg and HBeAg loss
Interferon alfa-2b vs. no treatment^82^ | 16/40 | 1/58 | 0.19 (-0.01; 0.39) (RD) | Low. Interferon alfa-2b vs. no treatment did not increase rates of negative HBV DNA and HBeAg seroconversion
Interferon alfa-2b vs. no treatment^89^ | 16/40 | 1/58 | 0.16 (-0.04; 0.35) (RD) | Low. Interferon alfa-2b vs. no treatment did not increase rates of negative HBV DNA, HBeAg loss
Interferon alfa-2b vs. no treatment^82^ | 16/40 | 1/58 | 0.27 (0.10; 0.43) (RD) | Low. Interferon alfa-2b vs. no treatment increased rated of negative HBV DNA, HBeAg loss and normal ALT
Interferon alfa-2b vs. no treatment^81,91^ | 16–96/40–144 | 2/92 | 0.28 (0.14; 0.42) (RD) 0.968/0% | Low. Sparse data (small number of events) Interferon alfa-2b vs. no treatment increased rates of negative HBV DNA and normal ALT
Entecavir vs. lamivudine^122,125^ | 52–63/76–87 | 2/995 | Random differences in all comparisons | Moderate. Entecavir, 0.50 or 0.1mg vs. lamivudine did not increase rate of HBV DNA and HBeAg loss
Interferon alfa 2b+prednisone vs. interferon alfa 2b^73,85^ | 24/48 | 1/56 | -0.17 (-0.42; 0.07) (RD) | Low. Interferon alfa-2b+pretreatment with prednisone vs. interferon alfa-2b alone did not increase rates of HBV DNA loss, HBeAg loss and seroconversion
24/48 | 1/79 | 0.07(-0.10;0.24)(RD)
Interferon alfa-2b+lamivudine vs. lamivudine^75^ | 52/75 | 1/75 | 0.21 (0.06; 0.35) (RD) | Low. Interferon alfa 2b+lamivudine vs. lamivudine alone increased rates of loss of HBVDNA+ HBeAg seroconversion+HBeAg loss
Peginterferon alfa-2b+lamivudine vs. lamivudine^106^ | 60/24 | 1/100 | 0.20 (0.05; 0.35) (RD) | Low. Peginterferon alfa-2+lamivudine vs. lamivudine alone increased rates of los of HBV DNA+HBeAg loss at two time points of followup
Peginterferon alfa-2b+lamivudine vs. lamivudine^106^ | 60/40 | 1/100 | 0.12 (-0.01; 0.25) (RD) | Low. Peginterferon alfa-2+lamivudine vs. lamivudine alone increased rates of los of HBV DNA+HBeAg loss at two time points of followup
60/57 | 1/100 | 0.20 (0.05; 0.35) (RD)

Effects of drugs on combined outcomes at the end of treatment. Interferon alfa-2b for 24 weeks with steroid pretreatment compared to no treatment with antiviral drugs increased rates of HBV DNA and HBeAg clearance (ARD 0.29, 95 percent CI 0.13; 0.46) in one RCT of 169 patients^84^ (Appendix E Figure 15). This study demonstrated an increase in HBV DNA and HBeAg clearance after 24 weeks of interferon alfa-2b administered at a dose of 35 MU/week (ARD 0.30, 95 percent CI 0.13; 0.46) but not 7 MU/week (ARD 0.10, 95 percent CI -0.04; 0.24).^84^ HBV DNA and HBeAg loss after interferon alfa-2b (35 MU/week) were larger compared to 7 MU/week (ARD 0.20, 95 percent CI 0.01; 0.38).^84^ Interferon alfa-2b for 16–96 weeks compared to no antiviral treatment increased rates of HBV DNA loss and normalization of ALT (pooled ARD 0.36, 95 percent CI 0.20; 0.51) in HBeAg-positive^81^ and HBeAg-negative patients.^91^ Lamivudine for 96 weeks compared to placebo increased HBV DNA loss and ALT normalization (ARD 0.46, 95 percent CI 0.32; 0.59) in HBeAg-negative Chinese patients.^139^

Comparative effects of interferon alfa-2b, 35 MU/week with steroid pretreatment on negative HBV DNA and HBeAg was larger compared to interferon, 7 MU/week alone.^84^ Interferon alfa-2b combined with lamivudine did not improve HBV DNA and HBeAg clearance and seroconversion compared to lamivudine alone.^75^ Entecavir or telbivudine did not improve combined outcomes at the end of monotherapy or in combination with lamivudine.^126,^ ^127^

Effects of drugs on combined outcomes at followup off treatment. Interferon alfa-2b increased rates of negative HBV DNA and HBeAg at 24–144 weeks off treatment with consistent results in relative terms (pooled RR 2.96, 95 percent CI 1.40; 6.25) (Appendix E Figure 13).^61,^ ^73,^ ^87,^ ^91^ Significant heterogeneity in absolute risk difference was observed (pooled ARD 0.22, 95 percent CI 0.08; 0.36) and could not be explained by differences across studies in control rate of the outcome or duration of treatments and followup (Appendix E Figure 16). Interferon alfa-2b compared to no treatment increased rates of negative HBV DNA, HBeAg loss, and normal ALT at 40 weeks of followup off treatments (ARD 0.27, 95 percent, 0.10; 0.43).^82^ Interferon alfa-2b compared to no treatment increased rates of negative HBV DNA and normalization of ALT (pooled ARD 0.28, 95 percent CI 0.14; 0.42).^81,^ ^91^ Interferon alfa-2b combined with lamivudine compared to lamivudine alone increased HBV DNA and HBeAg clearance and seroconversion (ARD 0.21, 95 percent CI 0.06; 0.35) in 75 treatment naïve patients.^75^

In conclusion, administration of interferon alfa-2b alone and in combination with lamivudine resulted in off treatment response in combined biochemical and virological outcomes in patients with HBeAg-positive CHB that was large in magnitude. Lamivudine alone increased rates of HBV and HBeAg loss at the end of the treatments but not at followup. The long-term effects of adefovir and telbivudine on combined outcomes have not been evaluated in RCTs.

Histological outcomes (Table 5). We analyzed histologic outcomes including changes in total, fibrosis, or necroinflammatory scores to assess effects of treatments on development of cirrhosis^177,^ ^178^ (Appendix E Tables 4 and 5). Liver biopsy is invasive and is associated with complications including pain, bleeding, infection, and rarely death.^179,^ ^180^ Histological results were not available in all subjects of the studies for unknown reasons. We analyzed the results among all randomized patients applying intention to treat principle.

Histological outcomes at the end of the therapy were reported in 22 publications^10,^ ^63,^ ^67,^ ^68,^ ^75,^ ^77,^ ^91,^ ^99,^ ^107,^ ^110^–^112,^ ^121,^ ^122,^ ^125,^ ^130,^ ^135,^ ^136,^ ^139,^ ^145^ and at followup off therapy in five studies (Appendix E. Table 5).^62,^ ^83,^ ^95,^ ^96,^ ^99^

Effects of drugs on histological outcomes at the end of treatment. Adefovir for 48–96 weeks improved necroinflammatory scores (decrease of at least two points in the Knodell necroinflammatory scores) compared to placebo (pooled ARD 0.26, 95 percent CI 0.17; 0.34) (Appendix E Figure 17).^10,^ ^110,^ ^112^ An improvement in fibrosis scores after adefovir administration was significant (pooled ARD 0.20, 95 percent CI 0.14; 0.26) but did not demonstrate dose response association.^110,^ ^112^ Lamivudine administration for 48–96 weeks improved necroinflammatory scores (decrease of at least two points in necroinflammatory scores) in all RCTs^130,^ ^136,^ ^139,^ ^145^ (pooled RR 2.09, 95 percent CI 1.60; 2.74). The effect on absolute risk was significant (pooled ARD 0.25, 95 percent CI 0.13; 0.38) but inconsistent across the studies (Appendix E. Table 5).^130,^ ^136,^ ^139,^ ^145^ Control rate of outcomes, duration of the treatment, a proportion of HBeAg-positive patients at baseline, and a proportion of untreated patients could not explain heterogeneity between studies. Entecavir compared to lamivudine improved necroinflammatory scores (ARD 0.14, 95 percent CI 0.04; 0.24) but without dose response association.^121,^ ^122,^ ^125^ Interferon alfa-2b combined with lamivudine for 48 weeks improved HAI scores compared to interferon alone (ARD 0.54, 95 percent CI 0.2; 0.79) in one RCT of 48 untreated HBeAg-positive Turkish patients.^68^

Effects of drugs on histological outcomes at followup off treatment. Histological improvement in necroinflammatory scores at 24 weeks of followup off treatment (ARD 0.12, 95 percent CI 0.02; 0.22) was reported in only one RCT^95^ after a 48 week administration of peginterferon alfa-2a compared to lamivudine in 552 HBeAg-negative patients.^95^

In conclusion, low-moderate quality evidence suggested improvement in histological scores at the end of monotherapy with adefovir or lamivudine. Off treatment improvement was reported only in HBeAg-negative patients after treatment with peginterferon alfa-2a compared to lamivudine. A higher level of certainty is not possible because reporting is from a relatively small number of short term, small studies, there is inconsistency in findings, and there are limitations in using liver biopsy findings to accurately assess overall histological changes due to treatments. The histological improvement in necroinflammatory scores reported with peginterferon compared to lamivudine was from only one study and at 24 weeks off therapy.

Normalization of ALT at the end of drug administration was reported in 35 publications^10,^ ^62,^ ^66,^ ^67,^ ^74^–^76,^ ^90,^ ^92,^ ^95,^ ^96,^ ^99,^ ^107,^ ^110^–^113,^ ^117,^ ^119^–^127,^ ^131,^ ^136,^ ^138^–^141,^ ^143,^ ^145^ and at followup off treatments in 24 studies^10,^ ^61^–^63,^ ^66,^ ^68,^ ^72,^ ^74^–^76,^ ^80,^ ^84,^ ^87,^ ^88,^ ^90,^ ^94^–^96,^ ^99,^ ^102,^ ^109,^ ^113,^ ^126,^ ^139^ (Appendix E. Tables 4 and 5).

Effects of drugs on ALT normalization at the end of treatment (Table 5). Adefovir for 48–96 weeks increased rates of ALT normalization compared to placebo in all RCTs (pooled RR 2.97, 95 percent CI 2.38; 3.69).^10,^ ^110,^ ^112,^ ^113^ However, the studies reported inconsistent differences in absolute rates of the outcome; such statistical heterogeneity in absolute risk difference (ARD 0.40, 95 percent CI 0.30; 0.49) could not be explained by the dose of adefovir, control rate, duration of the treatment, or the proportion of HBeAg-positive patients (Appendix E. Figure 18). Longer treatment with adefovir was associated with a decreased rate of ALT normalization (poled ARD -0.06, 95 percent CI -0.12; -0.01) without does response association.^10,^ ^111^–^113,^ ^120^

Lamivudine for 12–96 weeks increased ALT normalization with consistent effect size in relative risk compared to placebo or no antiviral treatment (pooled RR 2.42, 95 percent CI 1.94; 3.01).^67,^ ^131,^ ^136,^ ^139^–^141,^ ^145^ Heterogeneity in pooled absolute risk (pooled ARD 0.22, 95 percent CI 0.13; 0.31) could not be explained by the length of treatment, control rate, or the proportion of HBeAg-positive patients. Comparative effectiveness of entecavir on ALT normalization was greater compared to lamivudine with significant heterogeneity in relative (pooled RR 1.62, 95 percent CI 1.28; 2.06) and absolute risk (pooled ARD 0.22, 95 percent CI 0.11; 0.32).^90,^ ^121^–^126^ Heterogeneity could not be explained by the dose of entecavir, the duration of treatments, or the proportion of HBeAg-positive patients. The effect of entecavir on absolute risk of ALT normalization was lower in RCTs with higher rates of outcomes after lamivudine administration (meta-regression p value=0.005).

Lamivudine was less effective compared to adefovir (ARD -0.42, 95 percent CI -0.67; -0.18) in 38 American adults with compensated liver disease (Child-Pugh-Turcotte score <7) and lamivudine-resistant hepatitis B virus;^119^ however, lamivudine administration for 48 weeks was more effective in normalizing ALT compared to peginterferon alfa-2a in HBeAg-positive and negative patients (the Peginterferon Alfa-2a Chronic Hepatitis B Study Group, pooled RR for Peginterferon alfa-2a versus lamivudine 0.57, 95 percent CI 0.46;0.70).^95,^ ^96^ The absolute risk difference for peginterferon alfa-2a versus lamivudine was larger (ARD -0.36, 95 percent CI -0.45; -0.26) in HBeAg-negative patients^95^ than in HBeAg-positive patients (ARD -0.23, 95 percent CI -0.31; -0.15)^96^ (pooled ARD -0.29, 95 percent CI -0.42; -0.17). The same study reported that monotherapy with lamivudine resulted in greater ALT normalization compared to combined treatment (pooled ARD for peginterferon alfa-2a + lamivudine versus lamivudine -0.20, 95 percent CI -0.29; -0.10).^95,^ ^96^ In contrast, a combination of lamivudine with adefovir compared to monotherapy with lamivudine increased the rate of ALT normalization in lamivudine-resistant patients with compensated CHB (pooled ARD 0.32 95 percent CI 0.13; 0.52).^117,^ ^119^

Effects of drugs on ALT normalization at followup off treatment. ALT normalization at followup off treatments was greater after adefovir administration compared to placebo (pooled ARD 0.26, 95 percent CI 0.19; 0.33) in HBeAg-negative patients (the Adefovir Dipivoxil 438 Study Group)^10^ as well as in HBeAg-positive Chinese patients (Appendix E. Figure 19).^113^ Lamivudine for 96 weeks compared to placebo increased rates of ALT normalization at 24 weeks of followup off treatment (ARD 0.21, 95 percent CI 0.04; 0.38) in 139 HBeAg-negative Chinese patients.^139^ Interferon alfa-2b at doses 35 MU/week but not 7 MU/week compared to no antiviral treatment increased rates of ALT normalization at 8–24 weeks of followup (pooled ARD 0.31, 95 percent CI 0.17; 0.44).^84,^ ^87^ Interferon alfa-2b with steroid pretreatment increased ALT normalization compared to no antiviral drugs (ARD 0.25, 95 percent CI 0.06; 0.43)^84^ and random differences compared to interferon alfa-2b alone.^80,^ ^84,^ ^88^ In contrast with the superior effectiveness of lamivudine at the end of the treatment, sustained ALT normalization at 24 weeks of followup was greater after peginterferon alfa-2a compared to lamivudine (pooled ARD 0.13, 95 percent CI 0.07; 0.20)^95,^ ^96^ and after combined therapy of peginterferon alfa-2a with lamivudine compared to lamivudine alone (pooled ARD 0.13, 95 percent CI 0.06; 0.19).^95,^ ^96^

In conclusion, adefovir and lamivudine monotherapy resulted in ALT normalization that was maintained for up to 24 weeks. Longer term effects are not known. Entecavir and adefovir were more effective than lamivudine at the end of the treatment, while sustained differences have not been investigated. Peginterferon alfa-2b alone and combined with lamivudine normalized ALT at followup off the treatments when compared to lamivudine alone.

Relapse was defined as reappearance or increase in viral load^63,^ ^71,^ ^74,^ ^79,^ ^113,^ ^115,^ ^121,^ ^126,^ ^127,^ ^131^ or increase in HBV DNA and ALT levels^107^ at the end of active treatments or at followup off therapies^61,^ ^72,^ ^75,^ ^81,^ ^84,^ ^85,^ ^91,^ ^106,^ ^122^ (Appendix E. Tables 4 and 5). Lamivudine administration for 60 weeks compared to 48 weeks increased rates of virological relapse in one RCT of 348 HBeAg-positive Chinese patients.^131^ Entecavir administration for 52 weeks resulted in lower rates of viral relapse at 24 weeks of followup off treatments compared to lamivudine (ARD -0.16, 95 percent CI -0.20; -0.12) in 709 HBeAg-positive naïve to nucleoside analogue patients (participants in BEHoLD Study Group).^122^

Antiviral resistance (Table 5) was detected by the development of resistant HBV YMDD mutations (genotypic resistance) at the end of the treatments with reverse transcriptase inhibitors^63,^ ^67,^ ^74^–^76,^ ^79,^ ^110,^ ^111,^ ^115,^ ^117,^ ^131,^ ^132^ ^96,^ ^99,^ ^107^ or at followup off the therapies^10,^ ^62^ (Appendix E. Tables 4 and 5). Lamivudine administration for 52–130 weeks increased the rates of YMDD mutation compared to placebo by 43 percent (pooled ARD 0.43, 95 percent CI 0.38; 0.48).^67,^ ^132^ Longer treatments for 60 weeks versus 48 weeks resulted in larger rates of mixed (ARD 0.06, 95 percent CI 0.01; 0.11) and pure YMDD mutation (ARD 0.03, 95 percent CI 0.00; 0.06).^131^ Adefovir versus placebo increased rates of emerging amino acid substitutions in the HBV-RT domain and rates of rt221Y amino acid substitution but not rt134D; rt219A; rt91I; rt134N; rt54H; rt145M substitutions.^110,^ ^115^ Longer treatments for 240 versus 114 weeks increased rates of adefovir resistant mutations;^111^ however, combined therapy with adefovir plus lamivudine reduced the rates of YMDD compared to monotherapy with lamivudine (ARD -0.33, 95 percent CI -0.50; -0.17) in 135 patients with CHB and YMDD mutant HBV^117^ with random differences in wild type mutations. Interferon alfa-2b combined with lamivudine reduced rates of mutation compared to lamivudine alone with significant heterogeneity in relative (pooled RR 0.42, 95 percent CI 0.16; 1.09) and absolute risk (pooled ARD -0.18, 95 percent CI -0.35; -0.01).^63,^ ^67,^ ^74^–^76,^ ^79^ Heterogeneity could not be explained by the dose of interferon alfa-2b, length of treatment, or the proportion of HBeAg-positive patients at baseline. Lamivudine combined with interferon alfa-2b did not increase mutation rates compared to placebo in HBeAg-positive patients who had failed previous interferon therapy.^67^ Peginterferon alfa-2a with lamivudine compared to peginterferon alfa-2a alone increased the rate of mutation (ARD 0.03, 95 percent CI 0.01; 0.06) in the patients participating in the Peginterferon Alfa-2a HBeAg-Positive Chronic Hepatitis B Study Group.^96^ The same study reported reduced rates of mutations when peginterferon alfa-2a (ARD -0.25, 95 percent CI -0.31; -0.20) or peginterferon alfa-2a combined with lamivudine (ARD -0.22, 95 percent CI -0.28; -0.16) were compared to lamivudine monotherapy.^96^ At followup off treatments, interferon alfa-2b monotherapy (ARD -0.23, 95 percent CI -0.33; -0.14) or combined with lamivudine (ARD -0.23, 95 percent CI -0.32; -0.14) resulted in lower rates of mutations compared to lamivudine alone.^62^

In conclusion, limited evidence from a single trial suggested that a prolongation of lamivudine administration increased virological relapse in HBeAg-positive patients. Viral relapse post treatment was lower after entecavir compared to lamivudine in patients HBeAg-positive and naïve to nucleoside analogue. Lamivudine and adefovir increased the incidence of resistant HBV YMDD mutations, while combined therapy with interferon resulted in lower rate of mutation at the end of therapy and at followup. The effect on clinical outcomes including hepatocellular carcinoma and mortality is not known.

Effects of antiviral drugs on examined nonclinical outcomes at followup off treatments. Interferon alfa-2b resulted in sustained HBV DNA and HBeAg clearance and seroconversion and ALT normalization (Figure 4). A combination of interferon alfa-2b with steroid pretreatment or lamivudine did not maintain sustained HBV DNA and HBeAg loss at followup (Figure 5).

Figure 4. Off treatment effectiveness of monotherapy with interferon compared to no treatment (results from individual studies and pooled analysis with random effects model)

Figure 5. Off treatment effectiveness of combined therapy with interferon compared to placebo (results from individual studies and pooled analysis with random effects model)

Adefovir administration provided sustained ALT normalization and HBV DNA clearance without evidence of genotypic resistance (Figure 6). Lamivudine resulted in sustained HBV DNA and HBeAg clearance and ALT normalization. Entecavir compared to lamivudine reduced the rates of virological relapse at followup off therapy (Figure 7).

Figure 6. Off treatment effectiveness of reverse transcriptase inhibitors compared to placebo (results from individual studies and pooled analysis with random effects model)

Figure 7. Off treatment comparative effectiveness of monotherapy with interferon or reverse transcriptase inhibitors (results from individual studies and pooled analysis with random effects model)

Interferon alfa-2b combined with lamivudine compared to lamivudine sustained HBV DNA and HBeAg clearance and seroconversion and reduced rates HBV DNA mutations (Figure 8).

Figure 8. Off treatment comparative effectiveness of combined with interferon or reverse transcriptase inhibitors (results from individual studies and pooled analysis with random effects model)

Pegylated interferon alfa-2a was more effective compared to lamivudine in HBV DNA and HBeAg clearance and seroconversion and ALT normalization as well as in improved necroinflammatory scores (Figure 9). Combined therapy of pegylated interferon alfa-2a with lamivudine resulted in better sustained HBV DNA and HBeAg clearance and seroconversion and ALT normalization when compared to lamivudine alone but with random changes when compared to pegylated interferon alfa-2a alone (Figure 10).

Figure 9. Off treatment comparative effectiveness of monotherapy with pegylated interferon alfa-2a compared to lamivudine (results from individual studies and pooled analysis)

Figure 10. Off treatment comparative effectiveness of combined therapy with pegylated interferon alfa-2a and lamivudine (results from individual studies and pooled analysis)

Levels of viral load, biochemical, or histologic outcomes were evaluated in 27 publications after active and control treatments at the end of the therapy and at followup off therapy (Appendix E Table 6).^10,^ ^63,^ ^68,^ ^70,^ ^71,^ ^75,^ ^79,^ ^85,^ ^86,^ ^95,^ ^96,^ ^101,^ ^105,^ ^110,^ ^112,^ ^117,^ ^119^–^122,^ ^124,^ ^125,^ ^127,^ ^128,^ ^134,^ ^145^ Adefovir compared to placebo reduced serum HBV DNA levels by -1.65 log copies/ml (95 percent CI -2.08; -1.22) at 18 weeks of followup in HBeAg-negative patients (Adefovir Dipivoxil 438 Study Group).^10^ Telbivudine administration decreased viral load compared to adefovir at 28 weeks of followup (mean difference -0.84 log10 copies/ml 95 percent CI -1.49; -.19).^120^ Examined drugs failed to maintain sustained reduction in ALT level at followup.^10,^ ^75,^ ^86^ Necroinflammatory and fibrosis scores did not differ at followup off the treatments with interferon alfa-2b followed by steroid administration compared to interferon alfa-2b alone.^85,^ ^86^

In conclusion, measures of viral load, ALT levels, and histological scores at followup off the antiviral medications were evaluated in few studies without consistent differences between compared treatments.

### EPC Question 2b. What are the known harms associated with treatments of hepatitis B?

Literature search and review strategy. RCTs were identified through an Ovid MEDLINE^®^ search, using the search terms used to assess efficacy. Additional harms data were obtained from the FDA website and industry prescribing information. We excluded interferon trials that did not report type of interferon (2a or 2b) from the adverse events and lab abnormalities analyses.^75,^ ^77,^ ^181^

To address question 3 regarding particular patient populations that should not be treated, we describe whether adverse events and withdrawals varied by patient and/or disease characteristics and whether these seemed to be at high enough frequency or severity to preclude treatment.

Adverse events after nucleotide analogues (Appendix E Tables 4 and 7).

Adefovir monotherapy. Two randomized, double-blind, placebo-controlled trials (N=700), one enrolling HBeAg-positive^95^ and one HBeAg-negative chronic hepatitis subjects^110^ evaluated orally administered adefovir, an adenosine nucleotide analogue. Adefovir 10 mg/day was generally well tolerated, with rates of study withdrawal, adverse events, severe (Grade 3 or 4) adverse events, and adverse events leading to discontinuation similar to placebo over the 48 week study durations. Approximately 8 percent of both groups did not complete treatment for any reason. Fewer than 2 percent of all subjects had an adverse event leading to the discontinuation of study intervention (Table 6). In the trial with HBeAg-negative subjects, none of the serious adverse events were considered to be treatment-related.^110^ Most adverse events were generally mild to moderate in severity, with pharyngitis (23 percent versus 30 percent placebo) and flu-like syndrome (14 percent versus 19 percent placebo) the most commonly reported. Pooled analyses of the two RCTs from the prescribing information insert reported the most common events related to treatment were asthenia and headache, 13 and 9 percent versus 14 and 10 percent for placebo (www.fda.gov/medwatch/safety/2006/Oct_PIs/Hepsera_PPI.pdf). Long-term therapy (49–96 weeks) found adverse event similar in frequency and severity to those reported through week 48.^10^ Adverse event rates were comparable between nucleoside analogues lamivudine,^119^ telbivudine,^120^ and combination adefovir and lamivudine therapy (high level of evidence).

Table 6 Subjects withdrawing from treatment and experiencing adverse events from randomized controlled trials

Adverse Event | Number of Studies | Treatment n / N (%) | Control n / N (%) | Absolute Risk Difference [95% CI] | Relative Risk Ratio [95% CI] | Trial(s) Duration
A. Adefovir monotherapy
vs. placebo ^95,^ ^110^
Subjects not completing study / treatment | 1 | 26 / 345 (7.5) (10 and 30 mg) | 13 / 170 (7.6) | 0 [-5 to 5] | 0.99 [0.52 to 1.87] | 48 weeks
Any adverse event | 1 | 94 / 123 (76.4) | 45 / 61 (73.7) | 3 [-11 to 16] | 1.04 [0.87 to 1.24] | 48 weeks
Severe adverse event (grade III or IV) | 2 | 24 / 294 (8.2) | 19 / 228 (8.3) | 0 [-6 to 6] | 0.95 [0.45 to 2.01] | 48 weeks
AE leading to discontinuation of study drug | 2 | 4 / 294 (1.4) | 1 / 228 (<1) | 1 [-1 to 3] | 2.34 [0.37 to 14.75]
vs. lamivudine, subjects with lamivudine resistance ^119^
Subjects not completing study / treatment | 1 | 1 / 20 (5) | 1 / 19 (5.3) | 0 [-14 to 14] | 0.95 [0.06 to 14.13] | 48 weeks
Any adverse event | 1 | 18 / 19 (94.7) | 19 / 19 (100) | -5 [-19 to 8] | 0.95 [0.82 to 1.09] | 48 weeks
Serious adverse event | 1 | 3 / 19 (15.8) | 1 / 19 (5.3) | 11 [-9 to 30] | 3.0 [0.34 to 26.3] | 48 weeks
AE leading to discontinuation of study drug | 1 | 0 / 19 | 0 / 19 | 0 | -
vs. telbivudine ^120^
Subjects not completing study / treatment | 1 | 2 / 45 (4.4) | 2 / 45 (4.4) | 0 [-9 to 9] | 1.00 [0.13 to 7.43] | 52 weeks
Any adverse event | 1 | 27 / 44 (61.4) | 34 / 45 (75.6) | -14 [-33 to 5] | 0.81 [0.61 to 1.08] | 52 weeks
AE leading to discontinuation of study drug | 1 | 0 / 44 | 0 / 45 | 0 | -
B. Lamivudine monotherapy
vs. placebo ^136,^ ^139,^ ^145^
Subjects not completing study / treatment | 2 | 33 / 374 (8.8) | 16 / 120 (13.3) | -1 [-7 to 4] | 0.87 [0.51 to 1.49] | 52–104 weeks
Any adverse event | 1 | 224 / 285 (78.6) | 56 / 73 (76.7) | 2 [-9 to 13] | 1.02 [0.89 to 1.18] | 52 weeks
Serious adverse event | 2 | 18 / 374 (4.8) | 6 / 120 (5) | 2 [-1 to 4] | 1.24 [0.53 to 2.93] | 52–104 weeks
vs. placebo, subjects refractory interferon therapy ^67^
Subjects not completing study / treatment | 1 | 9 / 119 (7.6) | 10 / 56 (17.9) | -10 [-21 to 1] | 0.42 [0.18 to 0.98] | 68 weeks
AE leading to discontinuation of study drug | 1 | 1 / 119 (<1) | 4 / 56 (7.1) | -6 [-13 to 1] | 0.12 [0.01 to 1.03]
vs. placebo, subjects with advanced liver disease ^132^
Any adverse event | 1 | 335 / 436 (76.8) | 178 / 215 (82.8) | -6 [-12 to 0] | 0.93 [0.86 to 1.01] | 32 months (median)
Serious adverse event | 1 | 54 / 436 (12.4) | 38 / 215 (17.7) | -5 [-11 to 1] | 0.70 [0.48 to 1.03]
vs. placebo, HBV antigen-negative/ HBV DNA-positive (precore mutant) patients ^142^
Any adverse event | 1 | 40 / 65 (61.5) | 28 / 60 (46.7) | 15 [-2 to 32] | 1.32 [0.95 to 1.84] | 26 weeks
vs. pegylated interferon-α-2a monotherapy ^95,^ ^96^
Subjects not completing treatment / study | 2 | 71 / 456 (15.6) | 45 / 453 (9.9) | 6 [1 to 10] | 1.57 [1.10 to 2.22] | 72 weeks
Any adverse event | 2 | 238 / 453 (52.5) | 395 / 448 (88.2) | -36 [-43 to -29] | 0.59 [0.51 to 0.69] | 72 weeks
Serious adverse event | 2 | 10 / 453 (2.2) | 21 / 448 (4.7) | -2 [-5 to 0] | 0.47 [0.22 to 0.99] | 72 weeks
AE leading to discontinuation of study drug | 2 | 2 / 453 (<1) | 21 / 448 (4.7) | -5 [-10 to 1] | 0.13 [0.20 to 0.90] | 72 weeks
Dose modification due to AE | 2 | 0 / 453 | 33 / 448 (7.4) | -7 [-10 to -5] | 0.03 [0.00 to 0.22]
vs. combined pegylated Interferon-α-2a and Lamivudine ^95,^ ^96^
Subjects not completing treatment / study | 2 | 71 / 456* (15.6) | 49 / 457* (10.7) | 5 [1 to 9] | 1.45 [1.03 to 2.03] | 72 weeks
Any adverse event | 2 | 238 / 453 (52.5) | 395 / 450 (87.8) | -35 [-41 to -29] | 0.60 [0.52 to 0.68] | 72 weeks
Serious adverse event | 2 | 10 / 453 (2.2) | 28 / 450 (6.2) | -4 [-7 to -1] | 0.36 [0.18 to 0.73] | 72 weeks
AE leading to discontinuation of study drug | 2 | 2 / 453 (<1) | 19 / 450 (4.2) | -4 [-6 to -2] | 0.13 [0.03 to 0.47] | 72 weeks
Dose modification due to AE | 2 | 0 / 453 | 48 / 450 (10.7) | -10 [-15 to -6] | 0.02 [0.00 to 0.15]
C. Telbivudine monotherapy
vs. adefovir (see above)
vs. lamivudine, attributed to study drug (SEBIVO INSERT - 007 GLOBE) ^143^
Subjects not completing treatment / study | 1 | 18 / 680 (2.6) | 32 / 687 (4.7) | -2 [-4 to 0] | 0.57 [0.32 to 1.00] | 52 weeks
Any adverse event | | NR | NR | | | 52 weeks
Serious adverse event | 1 | 18 / 680 (2.6) | 33 / 687 (4.8) | -2 [-4 to 0] | 0.55 [0.31 to 0.97] | 52 weeks
AE leading to discontinuation of study drug | 1 | 2 / 680 (<1) | 5 / 687 (<1) | 0 [-1 to 0] | 0.40 [0.08 to 2.08] | 52 weeks
AE leading to discontinuation, possibly related to study drug | 1 | 1 / 680 myopathy | 1 / 687 urticaria | 0 [0 to 0] | 1.01 [0.06 to 16.12
D. Entecavir monotherapy (acyclic guanosine derivative)
0.5 mg dose vs. lamivudine, nucleoside-naïve subjects ^121,^ ^122^
Subjects not completing study / treatment | 2 | 37 / 688 (5.4) | 58 / 675 (8.6) | -3 [-8 to 2] | 0.64 [0.33 to 1.26] | E 56–75 weeks
Any adverse event | 2 | 552 / 679 (80.3) | 545 / 668 (81.1) | 0 [-6 to 6] | 1.00 [0.92 to 1.08] | L 56–65 weeks
Serious adverse event | 2 | 48 / 679 (7.1) | 54 / 668 (8.1) | -1 [-4 to 2] | 0.88 [0.60 to 1.27] | L 56–65 weeks
AE leading to discontinuation of study drug | 2 | 7 / 679 (1.0) | 18 / 668 (2.7) | -2 [-3 to 0] | 0.33 [0.06 to 1.86]
0.5 mg dose vs. lamivudine, nucleoside-naïve subjects. Patient information sheet (Bristol Myers Squibb)
Any Grade 2–4 adverse event | 1 | 102 / 679 (15) | 120 / 668 (18) | -3 [-7 to 1] | 0.84 [0.66 to 1.06] | Through 2 years
1 mg dose vs. lamivudine in lamivudine-refractory subjects. Patient information sheet (Bristol Myers Squibb)
Any Grade 2–4 adverse event | 2 | 40 / 183 (21.9) | 44 / 190 (23.2) | -1 [-10 to 7] | 0.94 [0.87 to 1.14] | Through 2 years
vs. lamivudine in lamivudine-refractory subjects ^124,^ ^125^
Subjects not completing study / treatment (48 weeks) | 2 | 39 / 283 (13.9) | 38 / 191 (19.9) | -12 [-30 to 6] | 0.54 [0.36 to 0.81] | 48 weeks
AE leading to discontinuation of study drug | 2 | 11 / 277 (4.0) | 14 / 190 (7.4) | -5 [-9 to 1] | 0.43 [0.12 to 1.54] | 48 weeks
Any adverse event | 2 | 225 / 277 (81.2) | 155 / 190 (81.6) | 0 [-12 to 11] | 0.99 [0.87 to 1.14] | 48 weeks
Serious adverse event | 2 | 22 / 277 (7.9) | 14 / 190 (7.4) | 1 [-4 to 6] | 1.18 [0.62 to 2.27]
E. Pegylated interferon-α-2a monotherapy (See lamivudine)
F. Combination pegylated interferon-α-2a and lamivudine therapy
vs. lamivudine (see above) ^95,^ ^96^
vs. pegylated interferon-α-2a monotherapy ^95,^ ^96^
Subjects not completing treatment / study | 2 | 49 / 457 (10.7) | 45 / 453 (9.9) | 1 [-4 to 5] | 1.08 [0.71 to 1.66] | 72 weeks
Any adverse event | 2 | 395 / 450 (87.8) | 395 / 448 (88.2) | 0 [-58 to 4] | 1.00 [0.95 to 1.05] | 72 weeks
Serious adverse event | 2 | 28 / 450 (6.2) | 21 / 448 (4.7) | 2 [-1 to 4] | 1.33 [0.77 to 2.30] | 72 weeks
AE leading to discontinuation of study drug | 2 | 19 / 450 (4.2) | 21 / 448 (4.7) | -1 [-6 to 4] | 0.90 [0.33 to 2.48]
G. Combination pegylated interferon-α-2b and lamivudine therapy (interferon)
vs. pegylated interferon-α-2b monotherapy ^99^
Subjects not completing treatment / study | 1 | 38 / 152 (25) | 37 / 155 (23.9) | 1 [-8 to 11] | 1.05 [0.71 to 1.55] | 78 weeks
Serious adverse event | 1 | 32 total, 17 probably related to therapy | | | | 78 weeks
AE leading to discontinuation of study drug | 1 | 12 / 152 (7.9) | 11 / 155 (7.1) | 1 [-5 to 7] | 1.11 [0.51 to 2.44]
I. Pegylated interferon-α-2b vs. interferon-α-2b ^109^
Subjects not completing treatment / study | 1 | 7 / 115 (6.1) | 20 / 115 (17.4) | -11 [-19 to -3] | 0.35 [0.15 to 0.80] | 72 weeks
AE leading to discontinuation of study drug | 1 | 0 / 115 | 4 / 115 (3.5) | -3 [-7 to 0] | 0.11 [0.01 to 2.04] | 72 weeks
Any adverse event | 75% of patients in each treatment group experienced various clinical forms of drug-related adverse effects.
K. Interferon-α-2b monotherapy (Interferon)
Prolonged (32 weeks) vs. standard (16 weeks) duration ^61^
Dose reduction due to AE | | 11.5% (7/61) in the prolonged group. Not reported in standard group.
AE leading to discontinuation of study drug | | 4.9% (3/61) in the prolonged group. Not reported in standard group.
Phase A - all subjects prior to randomization | | Dose modification due to AE: 16/162 (10%)
^91^ IFN (n=21) vs. no treatment (n=21). Study duration was 104 weeks. 5/21 (23.8%) IFN subjects withdrew from study. Dose in reduction in two subjects.
vs. no treatment
^90^ 6 months (n=19) vs. 12 months (n=19). “Treatment was well tolerated by all subjects who finished the study, and no dose modification was needed.”
^83^ IFN (n=20) vs. no treatment (n=20). Study duration was 68 weeks. 4 IFN and 5 NC subjects did not complete study.
^82^ IFN (n=30) vs. no treatment (n=28). Study duration was 10 months. One subject with a pre-existing depressive state converted to overt depression and was taken off treatment.
^81^ IFN (n=25) vs. no treatment (n=25). Study duration was 52 weeks. IFN therapy well tolerated, no serious AE observed.

Lamivudine monotherapy versus placebo. Several placebo-controlled RCTs evaluated the efficacy and safety of orally administered lamivudine (generally 100 mg/day) over 1 to 2 years.^136,^ ^139,^ ^145^ Similar to adefovir, lamivudine was generally well tolerated with no adverse events significantly greater than placebo. Fewer subjects randomized to placebo were likely to complete treatment compared to lamivudine, 13 percent versus 9 percent (ARD -1 percent, 95 percent CI -7; 4) in two trials^139,^ ^145^ and 18 percent versus 8 percent (ARD -10 percent, 95 percent CI -21; 1) in one trial enrolling subjects refractory to interferon.^67^ These differences were not statistically significant. The most common events were upper respiratory tract infections or symptoms, asthenia, abdominal pain, and headache. Overall, adverse events were similar between lamivudine and placebo in one study that enrolled subjects with advanced liver disease (histologically confirmed cirrhosis or advance fibrosis) with the exception of a greater incidence of diarrhea in the placebo group and cough in the lamivudine group over a median duration of treatment of 32 months.^132^ Rate of serious adverse events was slightly higher among the placebo group (18 percent) compared to the lamivudine group (12 percent), with an ARD of -5 percent (95 percent CI -11; 1). There were two deaths during therapy in the lamivudine group, one from lymphoma and one drowning due to a myocardial infarction (high level of evidence).

Lamivudine monotherapy versus peginterferon-alfa-2a monotherapy. Two RCTs, one with HBeAg-positive and one HBeAg-negative subjects, compared lamivudine 100 mg/day (n=456) to subcutaneously administered peginterferon-alfa-2a 180 μg/week monotherapy (n=453).^95,^ ^96^ Subjects were treated for 48 weeks and then followed up for an additional 24 weeks. Significantly more subjects assigned lamivudine discontinued treatment compared to the subjects assigned peginterferon-alfa-2a, 16 percent to 10 percent (RR 1.57, 95 percent CI 1.10; 2.22). However, more subjects treated with peginterferon alfa-2a were more likely to withdraw from a study due to an adverse event, 5 percent compared to <1 percent.(ARD -5 percent, 95 percent CI -10; 1). Dose modification due to an adverse event was required for 7 percent of peginterferon alfa-2a subjects and none of the lamivudine group. Most adverse events were significantly more frequent with peginterferon alfa-2a therapy. An initial flu-like illness was commonly associated with peginterferon alfa-2a treatment, noted by pyrexia, fatigue, myalgia, and headache. Approximately 18 percent of peginterferon alfa-2a subjects reported hair loss compared to 2 percent of lamivudine subjects. Anorexia was reported in 16 percent of peginterferon alfa-2a subjects. Events attributed solely to peginterferon alfa-2a included rigors and an injection-site reaction (due to the subcutaneously administration). Depression was reported in 5 percent and 2 percent of peginterferon alfa-2a and lamivudine subjects, respectively, (RR 0.31, 95 percent CI 0.10; 0.93). One subject receiving lamivudine developed hepatic decompensation after cessation of therapy and died.^96^ There was one death in the peginterferon-alfa-2a group.^95^ This subject had developed thrombotic thrombocytopenic purpura (moderate level of evidence).

Lamivudine monotherapy versus combination peginterferon alfa-2a and lamivudine therapy. Combined peginterferon alfa-2a and lamivudine had a similar adverse event profile as peginterferon alfa-2a when compared to lamivudine monotherapy in two trials reporting.^95,^ ^96^ More lamivudine subjects did not complete treatment but combination subjects were more likely to discontinue treatment due to an adverse event. Fifty-three percent of lamivudine subjects reported any adverse event compared to 88 percent of the combination subjects (ARD -35 percent, 95 percent CI -41; -29). Nearly 11 percent of the combination group required dose modification due to an adverse event, slightly higher than peginterferon monotherapy. The higher frequency of flu-like symptoms (pyrexia, fatigue, myalgia, and headache) was also observed with combination therapy compared to lamivudine as well as significantly greater incidences of hair loss (22 percent versus 2 percent), anorexia (13 percent versus 2 percent), and depression (6 percent versus 2 percent). There were three deaths in the combination group during the treatment period.^96^ These deaths were reported as accidental and unrelated to the study drug (low to moderate level of evidence).

Lamivudine monotherapy versus combination peginterferon alfa-2b and lamivudine therapy. One trial assessed combination peginterferon alfa-2b (1.5 μg/kg of body weight per week up to 100 μg) and lamivudine therapy (n=50) compared to lamivudine monotherapy (n=50) over 52 weeks.^107^ Combination therapy resulted in higher frequencies of transient flu-like adverse events, hair loss, and anorexia. Four subjects assigned combination therapy had serious adverse events, including one case of bipolar disorder requiring antidepressant treatment and one case of a severe local reaction. Peginterferon treatment was stopped for all cases.

Lamivudine monotherapy versus combination conventional interferon alfa-2b and lamivudine therapy. Six trials evaluated conventional interferon alfa-2b combined with lamivudine.^62,^ ^63,^ ^67,^ ^71,^ ^72,^ ^74^ Adverse event data were provided primarily by three of the studies.^62,^ ^63,^ ^67^ Combined therapy had a similar safety profile to the pegylated formulation, with high frequencies of pyrexia, headache, fatigue, and myalgia compared to lamivudine monotherapy. Similar to the pegylated formulation, there were significantly higher incidences of alopecia (30–40 percent versus <1–10 percent) and anorexia (19–40 percent versus <1–5 percent) compared to lamivudine monotherapy in two RCTs reporting.^62,^ ^67^ The trial with subjects refractory to interferon reported a significantly lower incidence of depression in the monotherapy group compared to combined therapy, 3 percent to 18 percent (ARD -15 percent, 95 percent CI -25; -5)^67^ (moderate level of evidence).

Telbivudine monotherapy. The GLOBE study evaluated orally administered L-nucleoside analog telbivudine 600 mg/day (n=683) against lamivudine 100 mg/day (n=687) in both HBeAg-positive and negative chronic hepatitis subjects over 52 weeks^143^ (www.fda.gov/cder/foi/label/2006/022011lbl.pdf). Compared to lamivudine, significantly fewer subjects receiving telbivudine withdrew from treatment or were noted to have a serious (Grade 3 or 4) adverse event. Less than 1 percent of subjects in both groups discontinued treatment due to an adverse event. One case of myopathy presumed to be treatment-related occurred in the telbivudine group. Comparable to adefovir and lamivudine, telbivudine is generally well tolerated; most adverse events are typically mild to moderate in severity. Incidences of adverse events were low in both groups (www.fda.gov/cder/foi/label/2006/022011lbl.pdf). In the trial versus adefovir, no serious adverse events were reported and no subject withdrew from therapy due to an adverse event^120^ (low level of evidence).

Adverse events after acyclic guanosine derivative.

Entecavir monotherapy. Two RCTs enrolling nucleoside-naive subjects compared entecavir 0.5 mg/day, an acyclic guanosine derivative was to lamivudine 100 mg/day.^121,^ ^122^ One trial enrolled HBeAg-positive subjects,^122^ and the other HBeAg-negative subjects.^121^ All subjects in both trials had not received treatment with a nucleoside analogue. Mean exposure to therapy was 56 to 75 weeks for entecavir and 56 to 75 weeks for lamivudine. Numbers of subjects not completing treatment, reporting any or serious adverse events were similar between treatments. More subjects in the lamivudine group were likely to discontinue treatment due to an adverse event. Rates of individual adverse events were not reported in the trials, but the most frequent events cited included headache, upper respiratory tract infection, upper abdominal pain, nasopharyngitis, dyspepsia, fatigue, back pain, arthralgia, diarrhea, insomnia, cough, and nausea. These events were noted to be mostly mild to moderate. There were four deaths considered unrelated to study therapy, two in both treatment groups. A slightly higher percentage of subjects randomized to lamivudine reported any Grade 2 to 4 adverse event through two years, 18 percent versus 15 percent for entecavir (Bristol Myer package insert). Pooled analysis of two studies enrolling subjects refractory to lamivudine found rates of any Grade 2 to 4 adverse events were similar between the entecavir 1 mg dose group and lamivudine group, 22 percent and 23 percent, respectively (Bristol Myer package insert). Three deaths were reported in one trial enrolling lamivudine-refractory subjects, none were deemed related to the study medication by the investigator^125^ (low to moderate evidence).

Adverse events after interferons.

Pegylated interferon alfa-2a versus lamivudine monotherapy and combination therapy (see above).

Combination of peginterferon alfa-2a and lamivudine therapy versus peginterferon alfa-2a monotherapy. Combined peginterferon alfa-2a and lamivudine had a similar safety profile and withdrawal rates compared with peginterferon alfa-2a monotherapy.^95,^ ^96^ The most common treatment-related adverse events in both groups included flu-like symptoms (pyrexia, fatigue, myalgia, and headache). Depression was reported by 6 percent (n=16) of the monotherapy group and 5 percent (n=13) of the combination group in one study enrolling HBeAg-positive subjects.^96^ Four subjects died during the study periods, one in the peginterferon alfa-2a group^95^ and three in the combined therapy group^96^ (low to moderate evidence).

Combination of pegylated interferon alfa-2b and lamivudine therapy versus pegylated interferon monotherapy. One 52 week (26 week followup period) trial enrolling 307 subjects evaluated combined pegylated interferon alfa-2b 100 μg/week and lamivudine therapy in comparison to pegylated interferon alfa-2b monotherapy.^99^ Approximately one-fourth of all subjects did not complete treatment. Between 7 and 8 percent discontinued treatment due to an adverse event. Overall, rates of adverse events were comparable between groups and the most common events were flu-like symptoms. There were 32 serious adverse events reported for both treatment arms. Seventeen events were likely to be attributed to therapy and included hepatitis flare (4), depression (3), severe neutropenia (3), and one case each of psychosis, seizures, pancreatitis, anxiety, dizziness, diarrhea, and syncope. All serious adverse events were reversible after treatment cessation. A study which followed these subjects an additional 26 weeks concluded that the most important predictors of dose reduction or study withdrawal were pre-existing cirrhosis and neutropenia^103^ (low level of evidence).

Pegylated interferon alfa-2b versus interferon alfa-2. One Chinese trial (N=230) compared pegylated interferon alfa-2b 1.0 μg/kg/week monotherapy to interferon alfa-2b 3 MU/week monotherapy.^109^ Significantly more subjects receiving conventional interferon did not complete treatment and followup compared to the pegylated interferon group, 17 percent versus 6 percent (ARD -11 percent, 95 percent CI -19; -3). Seventy-five percent of patients in each group reported drug-related adverse events, mainly flulike symptoms and fever. Adverse events lead to four subjects (4 percent) in the conventional interferon group to discontinue treatment.

Conventional interferon alfa-2b and lamivudine. One trial of interferon nonresponders to interferon compared 24 weeks of combined interferon alfa-2b 10 MU/week and lamivudine therapy (n=63) versus 52 weeks of placebo (n=56).^67^ The percentages of subjects not completing treatment were comparable. There were significantly more flu-like adverse events observed with interferon therapy in the combined group. A multinational trial comparing combined therapy (n=76) to interferon monotherapy (n=70) found rates of adverse events were similar between groups with the exception of headache, which had significantly higher incidence in the combined group (93 percent to 67 percent, ARD 26 percent, 95 percent CI 14; 39).^62^ A Turkish study of 49 subjects reported a significantly higher incidence of mouth dryness in the combined therapy group (76 percent) compared to the interferon monotherapy group (33 percent) (ARD 57 percent, 95 percent CI 33; 81).^68^

Interferon alfa-2b. Several RCTs compared different regimens of interferon alfa-2b therapy to no treatment. The trials reported that treatment was generally well-tolerated, but most subjects developed transient mild flu-like symptoms. In addition, Chung (N=65) reported anorexia/nausea in 22 percent of all subjects.^66^ Janssen noted dose reduction was required in 12 percent of subjects in the “Prolonged Treatment” group due to depression, fatigue, hair loss, and headache^61^ (low to moderate evidence).

Laboratory abnormalities/toxicities after nucleotide analogues. (Appendix E Tables 4 and 8).

Adefovir. In a pooled analysis of two trials, similar incidences of Grade 3 or 4 laboratory abnormalities were observed for adefovir and placebo with the exception of significant increases in ALT and AST levels (www.fda.gov/medwatch/safety/2006/Oct_PIs/Hepsera_PPI.pdf). Over 40 percent of placebo subjects had ALT levels more than five times the upper limit of normal (ULN) in the placebo group compared to 20 percent of the adefovir 10 mg group (RR 0.49, 95 percent CI 0.37; 0.65). AST levels greater than five times the ULN were observed in 23 percent and 8 percent of the placebo and adefovir subjects, respectively. An increase in serum creatinine ≥0.3 mg/dL from the baseline level was observed in 4 percent of adefovir subjects versus 2 percent of placebo subjects with adequate renal function at week 48 of treatment. No subject developed an increase ≥0.5 mg/dL at week 48. After extended adefovir treatment of an additional 48 weeks, two subjects had increases in serum creatinine ≥0.5 mg/dL from baseline, leading to discontinued treatment in one subject.^10^ A black box warning from the prescribing information states subjects with or at risk of impaired renal function may develop nephrotoxicity with chronic administration of adefovir (www.fda.gov/medwatch/safety/2006/Oct_PIs/Hepsera_PPI.pdf). An analysis of renal safety utilizing the study population of the trial by Marcellin^95^ found a greater occurrence of Grade 1 and 2 hematuria and proteinuria in the adefovir 30 mg group compared to placebo.^116^ In the trial versus telbivudine, one adefovir subject had an elevated serum creatinine level that returned to normal range after switching to telbivudine after study cessation.^120^ Grade 3 or 4 neutropenia was reported for one subject in each treatment arm. Each case resolved without dose reduction or treatment interruption. In one 48 week trial of lamivudine-refractory subjects, there were seven Grade 3 events (37 percent) compared to two Grade 3 and 4 events (10 percent) in the combined adefovir/lamivudine group^119^ (moderate to high evidence).

Lamivudine versus placebo. A one year placebo-controlled trial of 385 Chinese subjects reported 10 subjects had abnormal liver function tests considered to be of major clinical concern, five in the lamivudine group (2 percent; four received 100 mg and one 25 mg) versus five in the placebo group (7 percent) (RR 0.26, 95 percent CI 0.08; 0.86).^145^ A trial of 143 American subjects found the frequency of Grade 3 or 4 lab abnormalities similar between lamivudine and placebo during the course of treatment.^136^ However, 25 percent of lamivudine subjects had an ALT level at least three times the baseline level (Grade 3 or 4 abnormality) compared to eight percent of placebo subjects during the 16 week post-treatment period (p=0.01). In subjects with advanced liver disease, 12 percent of subjects receiving lamivudine had elevations in serum ALT at least three times the level at baseline compared to one-fourth of the subjects receiving placebo (ARD -13 percent, 95 percent CI -20; -7)^132^ (moderate evidence).

Lamivudine versus peginterferon alfa-2a monotherapy. Comparable to the adverse event profile, rates of lab abnormalities were significantly higher in the peginterferon alfa-2a monotherapy group compared to lamivudine. In a pooled analysis of two RCTs (N=901), dose modification was required for 46 percent of peginterferon alfa-2a recipients versus none of the lamivudine recipients (ARD -46 percent, 95 percent CI -51; -42.^95,^ ^96^ Approximately 37 percent (95 percent CI 32; 41) of peginterferon alfa-2a subjects required dose medication due to a lab abnormality (79 percent of all dose modifications), with neutropenia and thrombocytopenia cited as the most common causes (moderate evidence).

Lamivudine versus combination peginterferon alfa-2a and lamivudine therapy. Combined peginterferon alfa-2a and lamivudine had a similar lab abnormality profile as peginterferon alfa-2a monotherapy in two trials reporting (N=903).^95,^ ^96^ No subject assigned lamivudine required dose modification, while 47 percent of combined therapy subjects need alterations in the therapy regimen (ARD -47 percent, 95 percent CI -52; -43). Lab abnormalities accounted for 78 percent of all dose modifications, primarily due to neutropenia, thrombocytopenia and elevated ALT (moderate evidence).

Lamivudine versus combination peginterferon alfa-2b and lamivudine therapy. One Chinese trial randomizing 100 subjects assessed combination peginterferon alfa-2b and lamivudine therapy (n=50) compared to lamivudine monotherapy (n=50) over at least 78 weeks.^107^ Dose reduction was required for five (10 percent) pegylated interferon subjects due to anemia (one patient), neutropenia (three patients), and/or thrombocytopenia (four patients). One combined therapy subject had peginterferon withheld for two doses due to a severe hepatic flare-up. No lamivudine subject required a reduction of dose. There were no significant differences in the incidence of lab abnormalities between groups (low evidence).

Lamivudine versus combination conventional interferon alfa-2b and lamivudine therapy. Several trials evaluated conventional interferon alfa-2b combined with lamivudine compared to lamivudine monotherapy. One Italian trial (N=151) with a study duration of 100 weeks found no significance in rates of lab abnormalities between groups.^63^ One trial of interferon-refractory subjects noted similar frequencies of lab abnormalities between groups.^67^ Elevated ALT (≥2 times the baseline level) was significantly greater in the combined therapy group (n=63) during primary treatment, 48 percent versus 26 percent for the lamivudine group (n=119) (ARD -22 percent, 95 percent CI -36; -7). Incidence of neutropenia was also significantly greater among subjects assigned combined therapy, 16 percent versus 1 percent of lamivudine recipients. A Turkish trial (N=80) reported four cases of neutropenia occurred with combined therapy.^71^ Two cases each required temporary and permanent dose modification, respectively. Thrombocytopenia occurred in 11 cases (28 percent) in the combined therapy group versus three subjects in the lamivudine group (8 percent) (ARD -20 percent, 95 percent CI -36; -4) (moderate to high evidence and confidence).

Telbivudine. Significantly greater incidences in creatine kinase (CK) elevations were associated with telbivudine therapy compared to therapy with lamivudine. Data from the 52 week GLOBE trial showed 68 percent of telbivudine recipients (n=680) had a Grade 1–4 CK elevation compared to 39 percent of lamivudine subjects (n=687) (ARD 29 percent (95 percent CI 24; 34) product monograph (www.fda.gov/cder/foi/label/2006/022011lbl.pdf). Grade 3–4 CK elevations were reported for 7.5 and 3 percent of the telbivudine and lamivudine subjects, respectively. CK elevations decreased spontaneously to Grade 2 or lower in two-thirds of the telbivudine recipients and approximately three-fourths of the lamivudine subjects by the next clinical visit.^143^ In the telbivudine group, two subjects required discontinuation and three subjects required interruption of treatment due to CK toxicity product monograph (www.fda.gov/cder/foi/label/2006/022011lbl.pdf). There were higher frequencies of Grade 3–4 elevations in ALT and aspartate aminotransferase (AST) in the lamivudine group compared to the telbivudine group. ALT levels greater than three times the baseline level occurred in 6 percent of the lamivudine-assigned subjects versus 3 percent of the telbivudine subjects (RR 0.59, 95 percent CI 0.36; 0.95).^143^ Analysis of categories of ALT flares (≥2 times the baseline level) after 24 weeks of treatment found ALT flares were more likely to occur with lamivudine therapy (5 percent) than telbivudine (1 percent) product monograph (www.fda.gov/cder/foi/label/2006/022011lbl.pdf) (low to moderate evidence).

Laboratory abnormalities/toxicities after acyclic guanosine derivative.

Entecavir monotherapy. Elevations in ALT occurred more frequently in the lamivudine group (n=668) compared to the entecavir group (n=679), particularly during post-treatment.^121,^ ^122^ During the 24 week followup period, ALT flares (ALT >2 times the baseline level and >5 times the ULN) occurred in 24 percent and 9 percent of the lamivudine and entecavir groups, respectively (absolute risk difference -14 percent, 95 percent CI -21; -6). Elevations in ALT were also observed more frequently in the lamivudine group compared to entecavir 1 mg in a pooled analysis of two trials assessing lamivudine-refractory subjects through 2 years of study duration (N=373) [Patient information sheet, (Bristol Myers Squibb http://www.fda.gov/medwatch/safety/2007/Baraclude_PI_jul2407.pdf)]. ALT flares >5 times the ULN occurred in 24 percent of subjects assigned lamivudine versus 12 percent assigned entecavir (ARD -12 percent, 95 percent CI -20; -4). AST levels >5 times the ULN were also significantly greater in the lamivudine group (17 percent) compared to the entecavir group (5 percent) (ARD -12 percent, 95 percent CI -18; -6) (moderate evidence).

Laboratory abnormalities/toxicities after interferons.

Pegylated interferon alfa-2a versus lamivudine monotherapy and combination therapy (see above).

Combination peginterferon alfa-2a and lamivudine therapy versus peginterferon alfa-2a monotherapy. Combined peginterferon alfa-2a and lamivudine therapy and peginterferon alfa-2a monotherapy had similar laboratory abnormality profiles.^95,^ ^96^ Over 45 percent of both groups required dose modification. Nearly 80 percent of dose modifications were due to a lab abnormality, mainly neutropenia and thrombocytopenia. Elevated ALT levels occurred more frequently in the monotherapy group, 9 percent versus 4 percent (ARD -5 percent, 95 percent CI -10; 0)^95^ (low to moderate evidence).

Combination pegylated interferon alfa-2b and lamivudine therapy versus pegylated interferon monotherapy. No significant differences in dose modifications were reported between the treatment groups, and nearly 70 percent remained on full-dose treatment at the end of therapy.^99^ Frequencies of hematologic events, neutropenia (21–26 percent) and thrombocytopenia (11–13 percent), were also similar in the combined and monotherapy groups (low evidence).

Pegylated interferon alfa-2b versus interferon alfa-2. The trial by Zhao (N=230) reported four subjects (6 percent) in the conventional interferon group with elevated ALT levels and /or increased bilirubin levels discontinued treatment.^109^ No subjects in the pegylated group discontinued therapy due to a lab abnormality (low evidence).

Conventional interferon alfa-2b and lamivudine. In a trial evaluating subjects refractory to interferon treatment, frequencies of abnormal ALT or AST, abnormal enzymes and neutropenia were not significantly different from combined conventional interferon alfa-2b and lamivudine therapy (n=63) versus placebo (n=56) through the 68 treatments and followup duration.^67^ During the 52 week treatment period, 48 percent of combined therapy subjects had ALT levels at least two times the baseline level compared to 20 percent of placebo subjects (absolute risk difference 28 percent, 95 percent CI 12; 440. The Schalm trial found hepatic flares (ALT levels at least 500 IU/L and greater than two times the baseline level) were observed more frequently in the interferon monotherapy group (11 percent; 8/70 subjects) compared to combined therapy (0 percent; 0/75 subjects) during the 24 week treatment period.^62^ There was no difference in the incidence of flares during the 40-week post-treatment period (low evidence).

Interferon alfa-2b. Few of the small studies comparing different regimens of interferon alfa-2b therapy or to no treatment reported lab abnormalities. Low incidences (up to 6 percent) of thrombocytopenia and neutropenia were observed in three trials^61,^ ^66,^ ^81^ (low evidence).

## Consensus Conference Question 3 Which Persons With Hepatitis B Should be Treated?

### EPC Question 3a. Are there differences in efficacy/effectiveness of treatments for treatment naïve versus drug-resistant patients, HBeAg-positive versus HBeAg-negative patients, or for other subpopulations (as defined previously)?

We reviewed 15 studies that examined differences in treatment effects among patient subpopulations (as noted above) at the end of drug administration^61,^ ^64,^ ^75,^ ^93,^ ^105,^ ^107,^ ^124,^ ^130,^ ^132,^ ^133,^ ^135,^ ^140,^ ^141,^ ^143,^ ^145^ and at followup off active drugs (n=23)^61^–^65,^ ^72,^ ^73,^ ^75,^ ^84,^ ^85,^ ^90,^ ^93,^ ^96,^ ^97,^ ^99,^ ^100,^ ^102,^ ^104,^ ^106,^ ^108,^ ^109,^ ^114,^ ^126^ (Appendix E Table 9).

Clinical outcomes. Information is very limited because none of the studies reported mortality, liver related mortality, or hepatocellular carcinoma. Reported subgroup analyses appear to be exploratory in nature, varied in their definitions of outcomes and predictors and lack confirmatory findings. The French Multicenter Group^85^ conducted subgroup analysis of incident cirrhosis after 24 weeks of interferon alfa-2 with steroid administration among patients with baseline ALT more than three times the upper limit of normal and did not find significant protective effects of combined therapy compared to interferon monotherapy (RR 0.40, 95 percent CI 0.04; 4.19). One small Korean trial^141^ analyzed odds ratio of hepatic decompensation defined as an increase in Child-Turcotte-Pugh score of two or more points in patients with lamivudine-resistant mutants and found that gender, baseline HBeAg-positive status, and elevated ALT or viral load were not associated with progressive hepatic functional deterioration. However, patients with baseline platelet count less than versus greater than 65,000/μl experienced hepatic decompensation less often (RR 0.98, 95 percent CI 0.97; 0.99). Investigators for the Cirrhosis Asian Lamivudine Multicentre Study Group conducted subgroup analysis of overall disease progression, defined by hepatic decompensation, hepatocellular carcinoma, spontaneous bacterial peritonitis, bleeding gastroesophageal varices, or death related to liver disease in males and females treated with lamivudine or placebo and found significant protective effects of lamivudine in both genders (RR in males 0.53, 95 percent CI 0.33; 0.84 and in females 0.12, 95 percent CI 0.03; 0.58).^132^

In conclusion, little evidence is available regarding effectiveness of antiviral agents on clinical outcomes, especially to determine which groups should be treated or whether clinical outcomes vary according to key patient/disease characteristics. Clinical outcomes in Asian patients treated with lamivudine compared to placebo did not vary according to gender.

The vast majority of the studies described nonclinical outcomes among patient subgroups with different baseline liver enzymes, virological, or histological status. Even in these situations, studies did not provide power calculations and did not analyze baseline similarities in such subgroups. Analyses were exploratory in nature, lacked justification for subpopulation thresholds utilized, often were inconsistent in findings or thresholds employed, combined several different outcomes into a global effectiveness measure, and may have been selectively reported. Therefore, an accurate assessment and clear/concise summary is difficult (insufficient evidence).

Age (two studies, two antiviral agents, lamivudine and peginterferon, used as monotherapy). Limited evidence from two studies suggested that increased patient age was associated with lower sustained response to pegylated interferon alfa-2a or lamivudine as defined by HBV DNA clearance and ALT normalization. Younger patients had higher rates of HBV DNA clearance and ALT normalization (adjusted RR 1.26, 95 percent CI 1.00; 1.50) per 10 year decrease in age after 48 weeks of treatment and 24 weeks of treatment-free followup with peginterferon alfa-2a or lamivudine.^93^ Sustained response to pegylated interferon alfa-2a was lower (adjusted RR 0.39, 95 percent CI 0.16; 0.92) among patients above 25 years compared to those below.^109^

In conclusion, low levels of evidence suggested that decreased patient age was associated with enhanced treatment efficacy as measured by HBV DNA clearance and ALT normalization. No evidence was available for clinical outcomes.

Body weight (one study, Peginterferon Alfa-2a HBeAg-Negative Chronic Hepatitis B Study Group, two antiviral agents used as monotherapy). Patient body weight was not associated with sustained HBV DNA loss and ALT normalization after 48 weeks of treatment and 24 weeks of treatment-free followup with pegylated interferon alfa or lamivudine (adjusted RR 1.03, 95 percent CI 0.81; 1.3 per 10 kg increase in body weight).^93^

In conclusion, low levels of evidence suggested that baseline body weight is not associated with treatment efficacy as measured by HBV DNA loss and ALT normalization. No evidence was available for clinical outcomes.

Duration of hepatitis (one study- Lamivudine Italian Study Group Investigators, two antiviral agents used as combination therapy). Sustained virologic response at 48 weeks off therapy (suppression of serum levels of HBeAg and HBV DNA) to interferon alfa-2b combined with lamivudine was greater in those with an estimated duration of hepatitis of 10 years or less after adjustment for patient gender and age (adjusted OR 2.55, 95 percent CI 1.26; 19).^63^

In conclusion, low levels of evidence suggested that patients with longer duration of hepatitis responded to lamivudine therapy 2.5 times less frequent compared to those with shorter duration of the disease. No evidence was available for clinical outcomes or other therapies.

Gender (five studies, three antiviral agents, peginterferon, interferon, and lamivudine, used as monotherapy). Patient gender demonstrated inconsistent associations in five studies that evaluated this factor.^72,^ ^93,^ ^109,^ ^132,^ ^141^ One study reported that adjusted odds ratios of sustained combined response (ALT normalization and HBV DNA level <20,000 copies/ml) 24 weeks off peginterferon alfa-2a or lamivudine therapy was greater among women compared to men (OR 1.93, 95 percent CI 1.1; 3.4).^93^ The association was not significant at year 1 off treatment (OR males versus females 0.68, 95 percent CI 0.34; 1.37).^93^ Multivariate adjusted odds ratio of sustained 24 week off therapy combined response (HBeAg-negative, HBV DNA <5 log 10 copies/mL, and normal ALT level) to peginterferon alfa-2b or interferon alfa-2b was not significant (OR 0.59, 95 percent CI 0.22; 01.6) in males compared to females.^109^

In conclusion, low levels of evidence suggested that disease progression or treatment induced sustained ALT normalization and HBV DNA clearance did not vary by gender.

Baseline histology (four studies, three antiviral agents, peginterferon, interferon, and lamivudine, used as mono or combination therapy). Lamivudine administration compared to placebo reduced overall disease progression, defined as an increase of at least two points in the Child-Pugh score in patients with baseline Child-Pugh score 5–6 or baseline Ishak fibrosis score = 6 but not in those with baseline Child-Pugh score >7 and Ishak fibrosis score <4 or 5^132^ (Appendix E Table 10). Lamivudine compared to placebo increased HBeAg clearance among patients with baseline HAI scores >5 but failed in those with pretreatment HAI Score 0–4.^64^ HBeAg loss was 117 percent higher per unit increase in baseline HAI score (adjusted RR 1.17, 95 percent CI 1.10; 1.24).^64^ Lamivudine improved histology compared to placebo among patients with moderate or severe hepatitis (RR 2.30, 95 percent CI 1.39; 3.81) but failed in those with mild hepatitis.^145^

Interferon alfa-2b increased maintained HBeAg loss off treatment compared to placebo among patients with pretreatment HAI score 5–9 (RR 5.76, 95 percent CI 1.48; 22.42) but failed in patients with pretreatment HAI score 0–4 or >10.^64^ The same trial reported that interferon alfa-2b combined with lamivudine compared to placebo increased sustained HBeAg clearance in the same subpopulation with pretreatment HAI score 5–9 (RR 5.32, 95 percent CI 1.51; 18.72) with no effects in those with pretreatment HAI score 0–4 (RR 3.39, 95 percent CI 0.89; 12.87) or >10 (RR 1.79, 95 percent CI 0.89; 3.59).^64^ Off treatment virologic response to interferon alfa-2b combined with lamivudine increased in those with a baseline HAI Knodell inflammation score of seven or more, independent of gender and age (adjusted RR 2.91, 95 percent CI 1.04; 8.22).^63^ Baseline fibrosis scores were not associated with better sustained response to this treatment.^63^ Presence of steatosis did not modify the effect of peginterferon alfa-2a combined with lamivudine on sustained response defined as HBV DNA disappearance and ALT normalization in both HBeAg-positive and negative patients;^97^ however, the adjusted rates of sustained response were greater per increase in baseline Knodell HAI (adjusted OR 14.97, 95 percent CI 2.43; 92.28).^97^

In conclusion, there was a low level of evidence that treatment induced followup histology, HBeAg loss or DNA disappearance and ALT normalization varies by baseline histology severity. There was no evidence for clinical outcomes.

Baseline viral load (eight studies, three antiviral agents, peginterferon, interferon, and lamivudine, as mono or combination therapy) (Appendix E Tables 9 and 10). Lamivudine was more effective in patients with higher baseline HBV DNA levels. HBV DNA loss increased among patients with baseline HBV DNA >1.6pg/ml (RR 6.41, 95 percent CI 3.92; 10.47),^140^ and disease progression (defined as increase of at least two points in the Child-Pugh score) was lower in patients with baseline HBV DNA >100 meq/ml;^132^ however, dose response was not significant (HBeAg loss did not differ per 10-unit increase baseline HBV-DNA level).^64^

At followup off the treatment, interferon alfa-2b, 5MU/day compared to no treatment increased HBV DNA and HBeAg loss among patients with baseline HBV DNA 2-99 pg/ml (RR 5.24, 95 percent CI 1.22; 22.50) but failed among those with baseline HBV DNA 100–200 pg/ml or >200 pg/ml^84^ without a significant HBV DNA unit dose response association (RR 1.87, 95 percent CI 0.59; 5.87 per one unit increase in HBV DNA).^61^ Interferon alfa 2b, 10 MU three times per week versus no antiviral treatment increased sustained rates of HBeAg loss among patients with baseline HBV DNA <10pg/ml (RR 3.18, 95 percent CI 1.25; 8.05) but failed in those with higher viral load HBV DNA >10pg/ml.^61^ Interferon alfa-2b with steroid pretreatment increased sustained off treatment rates of HBV and HBeAg loss among patients with baseline HBV DNA 2-99 pg/ml (RR 5.38, 95 percent CI 1.26; 22.84) but failed in those with elevated baseline viral load (HBV DNA >100 pg/ml).^84^ While monotherapy with interferon alfa-2b was more effective in patients with lower compared to elevated baseline HBV DNA, combined administration of interferon alfa-2b with lamivudine resulted in greater sustained HBV DNA loss and HBeAg seroconversion in patients with elevated baseline HBV DNA >10^7^ copies/mL.^75^ Peginterferon alfa-2a resulted in greater sustained response compared to lamivudine in patients with baseline HBV DNA range of 25–75 percentile^93,^ ^96^ with random differences among those below 25 percent or above the 75th percentile. Sustained combined response was increased by one log 10 unit (copies/ml) decrease in baseline HBV DNA (adjusted OR 1.28, 95 percent CI 1.10; 1.40).^93^ Baseline mean viral load (copy/mL) was not associated with sustained response to the combined therapy with peginterferon alfa-2a plus lamivudine versus lamivudine alone.^97^

In conclusion, there was a low level of evidence that treatment induced HBeAg loss, DNA normalization, or histology varies with baseline viral load. There was no evidence for clinical outcomes.

#### Baseline HBeAg status (Appendix E Tables 9 and 10)

Evidence from trials that combined patients with HBeAg-negative and positive baseline status. Lamivudine at the end of 130 week administration decreased disease progression defined by hepatic decompensation, hepatocellular carcinoma, spontaneous bacterial peritonitis, bleeding gastroesophageal varices, or death related to liver disease compared to placebo among patients HBeAg-positive at baseline (RR 0.30, 95 percent CI 0.16; 0.55).^132^ There were no significant effects among HBeAg-negative patients (RR 0.72, 95 percent CI 0.36; 1.43).^132^ Entecavir in a dose of 1mg/day compared to lamivudine resulted in higher rates of undetectable HBV DNA and normal ALT level among patients with HBeAg-negative baseline status (RR 18.38, 95 percent CI 1.18; 285.96) with random differences in HBeAg-positive patients.^124^ Telbivudine compared to lamivudine reduced the rates of detectable HBV DNA (RR 0.67, 95 percent CI 0.54; 0.82) and improved necroinflammatory scores, with no worsening in the Knodell fibrosis score (RR 1.15, 95 percent CI 1.03; 1.27) among patients with HBeAg-positive baseline status with random differences in HBeAg-negative patients.^143^ Telbivudine compared to lamivudine for 52 weeks in Chinese patients with compensated hepatitis B resulted in better outcomes in HBeAg-positive patients with no difference in small subsample of HBeAg-negative patients. ^57^

Evidence from trials that included exclusively patients with HBeAg-negative status (11 studies; four antiviral agents used as mono or combination therapy). We reviewed the drug effects reported in the RCTs that enrolled all HBeAg-negative patients,^10,^ ^71,^ ^74,^ ^76,^ ^79,^ ^81,^ ^91,^ ^93,^ ^95,^ ^110,^ ^111^ including the Peginterferon Alfa-2a HBeAg-Negative Chronic Hepatitis B Study Group^93,^ ^95^ and the Adefovir Dipivoxil 438 Study Group^10,^ ^110,^ ^111^ (Table 7). Adefovir improved biochemical, virological, and histological outcomes in HBeAg-negative patients at the end of drug administration and at followup off the treatment without development of genetic mutations.^10,^ ^110^ Interferon alfa-2b combined with lamivudine was not more effective compared to lamivudine alone to improve combined virologcial with biochemical^71^ or virological^71,^ ^74,^ ^76^ outcomes in HBeAg-negative patients but lowered the rates of relapse defined as reappearance of detectable serum HBV DNA by polymerase chain reaction (PCR) after an initial virologic response^74^ and genetic viral mutations.^76^ Interferon alfa-2b compared to no antiviral treatments increased sustained HBV DNA clearance and ALT normalization in a large RCT^81^ with random differences in a small study;^91^ however, it failed to increase HBsAg loss and did not improve histological scores.^91^ Peginterferon alfa-2a compared to lamivudine improved sustained biochemical and virological outcomes and necroinflammatory scores but failed to improve fibrosis scores.^95^ Peginterferon alfa-2a combined with lamivudine compared to lamivudine improved sustained biochemical and virological outcomes with no differences on liver histology.^95^

Table 7 Effects of antiviral drugs on HBeAg-negative patients (relative risk from individual RCTs)

Treatments | Clinical or Combined Outcomes | Biochemical | Virological (HBV DNA, HBsAg) | Histological | Mutation
Adefovir (dose, time) | | NS^10^ | HBsAg seroconversion-NS^10^ HBV DNA loss- NS^10^ | Improved histology-NS^10^ | NS^10^
Adefovir vs. placebo | | 2.45 (1.61; 3.73) 1.79 (1.07; 3.00)* ^10,^ ^110^ | HBsAg seroconversion^10^ 1.52 (0.06; 36.46) loss HBV DNA^110^ 63.50 (4.00; 1009.28) loss HBV DNA ^10^* 8.83 (2.94; 26.52) | Failure^110^ 0.11 (0.04; 0.27) Improved^10,110^ Significant improvement in necroinflammatory or fibrosis scores with NS changes in total scores | NS^10,110^
Interferon alfa 2b+lamivudine vs. lamivudine | NS^71^ | Flare-NS^71,74^ Normalization of ALT: 1.29 (0.89; 1.86)^74^ 1.30 (0.46; 3.71)^74^ 1.08(0.82;1.41)^76^ 1.45 (1.02; 2.05)^76^* | HBV DNA loss-NS^71,^,^74,76^ Relapse 0.30 (0.09;0.93)^74^ HBsAg loss-NS^71,^,^74,76^ | | 0.03 (0.00; 0.55) 0.18 (0.04; 0.73) ^76^
Interferon alfa 2b vs. no treatment | Loss of HBV DNA and normalization of ALT^81^* 5.50 (1.36; 22.32) Loss of HBV DNA and normalization of ALT^91^* 13(0.78; 217.03) Relapse - NS^81^* 2.00(0.40; 9.95) | Flare 0.27 (0.11; 0.67)^91^ | HBsAg loss - NS ^91^ | Improved histology-NS ^91^ Resistance-NS^91^
Peginterferon alfa-2a+lamivudine vs. lamivudine | Normalization of ALT and loss of HBV DNA^95^* 2.64 (1.36; 5.11) | Normalization ALT^95^ 0.66 (0.55; 0.79) Normalization ALT*^95^ 1.34 (1.09; 1.64) | HBV DNA loss^95^ 1.17 (1.06; 1.30) HBV DNA loss*^95^ 2.92 (1.57; 5.44) | Failure NS^95^ Improved histology-NS^95^
Peginterferon alfa-2a+placebo vs. lamivudine | Normalization of ALT and HBV DNA loss*^95^ 2.36 (1.20; 4.64) | Normalization ALT^95^ 0.51 (0.41; 0.63) Normalization ALT*^95^ 1.31 (1.07; 1.61) | HBV DNA Loss^95^ 0.84 (0.73; 0.97) 2.83 (1.52; 5.29)* | Failure NS^95^ Improved necroinflammatory scores^95^* 1.39 (1.06; 1.82) Improved HAI-NS*^95^ Improved fibrosis-NS^95^

* off treatment; NS = not significant

In conclusion, low level of evidence suggested that lamivudine monotherapy decreased disease progression among patients HBeAg-positive at baseline but not in HBeAg-negative patients. Telbivudine increased viral clearance and improved histology compared to lamivudine in HBeAg-positive but not in HBeAg-negative patients. Entecavir was more effective compared to lamivudine in HBeAg-negative patients to increase viral clearance and ALT normalization. Patients without HBeAg at baseline experienced improvement in biochemical, virological, and histological outcomes after adefovir therapy and pegylated interferon alfa-2a monotherapy or combination with lamivudine. There was no evidence for clinical outcomes.

Baseline liver function (ten studies, three medications, peginterferon, interferon, and lamivudine were used as mono or combination therapy) (Appendix E Tables 9 and 10). The effects of lamivudine on disease progression defined as hepatocellular carcinoma, spontaneous bacterial peritonitis, bleeding gastroesophageal varices, or death related to liver disease or liver decompensation at the end of the treatment did not differ among patients with different baseline ALT levels (Appendix E Figure 20).^93,^ ^107,^ ^132,^ ^141^ Comparative effectiveness of peginterferon alfa-2a versus lamivudine on combined response defined as ALT normalization and an HBV DNA level of <20 000 copies/ml at the end of the treatment was greater per increase by 1 log 10 unit (IU/1) in baseline ALT levels (Table 8).^93^ Lamivudine increased HBeAg clearance and seroconversion among patients with elevated baseline ALT with no effects in those with ALT <2 ULN (Appendix E. Figure 21).^64^

Table 8 Effects of antiviral drugs for chronic hepatitis B on off treatment outcomes in patient subpopulations

Outcome | Comparison | Weeks of Treatments/ Followup off the Treatment | N Studies/ Enrolled | Author | Relative Risk or Odds Ratios (95% CI) | Level of Evidence From Individual Studies is Low for All Comparisons/Comments
Baseline ALT
HBV DNA loss | Interferon alfa 2b+corticosteroid vs. interferon alfa 2b | 24/24 | 1/115 | Wai, 2002^65^ | 1.22 (1.05; 1.42) | HBV DNA loss was more frequent among patients with elevated baseline ALT
HBV DNA and HBeAg loss | Interferon alfa 2b+corticosteroid vs. no treatment | 24/24 | 1/43 | Perrillo, 1990^84^ | 7.82 (1.02; 59.88) | Loss of HBV DNA and HBeAg was greater among patients with baseline ALT <100U/L with random differences among those with baseline ALT 100–200 and >200U/L
Odds ratio of HBeAg and HBV DNA loss independent of gender and age | Interferon alfa 2b+lamivudine vs. lamivudine | 24/48 | 1/150 | Barbaro, 2001^63^ | 3.12 (1.43; 6.82) | Adjusted odds of virologic response were higher in patients with baseline ALT >150UL
HBeAg loss | Interferon alfa 2b+lamivudine vs. placebo | 24/28 | 1/331 | Perrillo, 2002^64^ | 2.90 (1.35; 6.27) | HBeAg loss was higher among patients with ALT >2 but <5ULN with random differences among those with <1ULN or 1–2ULN
HBeAg seroconversion | Interferon alfa 2b+lamivudine vs. placebo | 24/28 | 1/331 | Perrillo, 2002^64^ | 2.70 (1.10; 6.58) | HBeAg seroconversion was greater among patients with >2–<5 ULN
3.27 (1.03; 10.39) | HBeAg seroconversion was greater among patients with ALT >5 ULN with random differences among those with baseline ALT<1ULN or 1–2ULN
Adjusted for treatment status odds ratio of HBeAg seroconversion, HBV DNA loss and ALT normalization in HBeAg (+) patients. In HBeAg (-) patients: loss of HBV DNA+ALT normalization | Peginterferon alfa-2a+lamivudine vs. lamivudine | 9/24 | 1/140 | Cindoruk, 2007^97^ | 10.32 (9.71; 10.97) | Sustained response was greater per increase in 1unit (U/L) in baseline ALT
HBeAg seroconversion | Peginterferon alfa-2a+lamivudine vs. lamivudine | 48/24 | 1/542 | Lau, 2005^96^ | 1.93 (1.01; 3.69) | Response was greater among patients with baseline ALT >5ULN, random differences among those with baseline ALT <2 or 2–5ULN
HBeAg seroconversion | Peginterferon alfa-2a+placebo vs. lamivudine | 48/24 | 1/542 | Lau, 2005^96^ | 1.81 (1.07; 3.04) | HBeAg seroconversion was greater in patients with baseline ALT >2 but <5ULN. Random differences among those with baseline ALT <2 or >5ULN
Adjusted odds ratios of ALT normalization and an HBV DNA loss | Peginterferon alfa-2a vs. lamivudine | 48/24 | 1/1036 | Bonino, 2007^93^ | Random association per 1 U/L increase in baseline ALT
Adjusted for treatment allocation, HBV genotype and log HBV DNA odds ratio of HBeAg loss | Peginterferon alfa-2b+lamivudine vs. lamivudine | 60/24 | 1/100 | Chan, 2006^108^ | Random association per 1 U/L increase in baseline ALT
Adjusted odds ratio of sustained HBeAg loss | Peginterferon alfa-2b+lamivudine vs. peginterferon alfa-2b | 52/26 | 1/310 | Janssen, 2005^99^ | Random differences among patients with elevated vs. normal baseline ALT
Adjusted odds ratio of HBeAg and HBV DNA loss, and normal ALT level | Peginterferon alfa-2b+vs. interferon alfa 2b | 24/24 | 1/230 | Zhao, 2007^109^ | 1.23 (0.51; 2.92) | RR, random differences between patients with baseline ALT level >3.4 vs. <3.4 ULN
Baseline histology
HBeAg loss | Interferon alfa 2b vs. placebo | 24/28 | 1/264 | Perrillo, 2002^64^ | 5.76 (1.48; 22.42) | Interferon alfa 2b vs. placebo increased HBeAg loss among patients with pretreatment HAI score 5–9 but failed among patients with pretreatment HAI score 0–4 or >10
HBeAg loss | Interferon alfa 2b+lamivudine vs. placebo | 24/28 | 1/331 | Perrillo, 2002^64^ | 5.32 (1.51; 18.72) | Interferon alfa 2b+lamivudine vs. placebo increased HBeAg loss in patients with pretreatment HAI Score 5–9 but failed among patients with pretreatment HAI score 0–4 or >10
Odds ratio of HBeAg and HBV DNA loss independent on gender and age | Interferon alfa 2b+ lamivudine vs. lamivudine | 24/48 | 1/151 | Barbaro, 2001^63^ | 2.91 (1.04; 8.22) | The rate of sustained response after interferon alfa 2b+ lamivudine vs. lamivudine was increased by an increase in baseline inflammation scores
2.58 (0.88; 7.60) | The rate of sustained response after interferon alfa 2b+ lamivudine vs. lamivudine was not increased by an increase in baseline fibrosis scores
Adjusted for treatment status odds ratio of HBeAg seroconversion, HBV DNA loss and ALT normalization in HBeAg (+) patients. In HBeAg (-) patients: loss of HBV DNA, ALT normalization | Peginterferon alfa-2a+lamivudine vs. lamivudine | 9/15 | 1/160 | Cindoruk, 2007^97^ | Presence of steatosis did not modify the effect of peginterferon alfa-2a + lamivudine vs. lamivudine on sustained response
14.97 (2.43; 92.28) | The adjusted rates of sustained response were increased per increase in baseline Knodell HAI
Adjusted relative risk of HBeAg seroconversion and HBV DNA loss | Peginterferon alfa-2b+lamivudine vs. peginterferon alfa-2b | 52/78 | 1/310 | Buster, 2007^100^ | 0.98 (0.17; 5.23) | Presence of advanced fibrosis- fibrosis score of 4–6 (HAI) did not change adjusted relative risk of HBV DAN loss and HBeAg seroconversion
Baseline viral load
HBV DNA loss with persistent HBeAg | Interferon alfa 2b vs. no treatment | 32/20–52 | 1/118 | Janssen, 1999^61^ | 1.87 (0.59; 5.87) | No association between baseline positive HBV DNA (per 1 unit increase) and the effects of interferon alfa 2b vs. no treatment
HBV DNA and HBeAg loss | Interferon alfa 2b vs. no treatment | 24/24 | 1/169 | Perrillo, 1990^84^ | 5.24 (1.22; 22.50) | interferon alfa 2b, 5MU/day vs. no treatment increased rates of HBV DNA and HBeAg loss among patients with baseline HBV DNA 2-99pg/ml. Random differences after interferon 1MU/day and after interferon 1 or 5 MU/day among the patients with baseline HBV DNA 100–200 pg/ml or >200 pg/ml
HBeAg loss | Interferon alfa 2b vs. no treatment | 32/20 | 1/118 | Janssen, 1999^61^ | 3.18 (1.25; 8.05) | RR, Interferon Alfa 2b, 10 MU three times per week vs. no treatments increased rates of HBeAg loss among the patients with baseline HBV DNA <10pg/ml. Random differences among the patients with baseline HBV DNA >10pg/ml
HBV DNA and HBeAg loss | Interferon alfa 2b+corticosteroid vs. no treatment | 24/24 | 1/169 | Perrillo, 1990^84^ | 5.38 (1.26; 22.84) | interferon alfa 2b+corticosteroid vs. no treatment increased rates of HBV and HBeAg loss among patients with baseline HBV DNA 2-99pg/ml
HBV DNA and HBeAg loss | Interferon alfa 2b+corticosteroid vs. no treatment | 24/24 | 1/169 | Perrillo, 1990^84^ | 8.80 (0.49; 158.66) | interferon alfa 2b+corticosteroid vs. no treatment did not increase the rates of HBV DNA and HBeAg loss among patients with baseline HBV DNA 100–200 pg/ml
0.98 (0.06; 15.13) | interferon alfa 2b+corticosteroid vs. no treatment did not increase the rates of HBV DNA and HBeAg loss among patients with baseline HBV DNA >200 pg/ml
HBeAg loss | Interferon alfa 2b+corticosteroid vs. interferon alfa 2b | 24/24 | 1/183 | Wai, 2002^65^ | 1.10 (1.03; 1.17) | Interferon alfa 2b+corticosteroid vs. interferon alfa 2b increased the rates of HBeAg loss in patients with low baseline HBV-DNA level
1.10 (1.01; 1.21) | Interferon alfa 2b+corticosteroid vs. interferon alfa 2b increased the rates of HBeAg loss in patients with low baseline HBV-DNA and elevated baseline ALT
Odds ratio of HBeAg and HBV DNA loss | Interferon alfa 2b+lamivudine vs. lamivudine | 24/48 | 1/151 | Barbaro, 2001^63^ | 7.23 (2.71; 19.57) | Odds of sustained suppression of serum levels of HBeAg and HBV DNA was significant in those with baseline viral load of 200 pg/ml or less independent of gender and age
HBeAg loss | Interferon alfa 2b+lamivudine vs. lamivudine | 52/24 | 1/75 | Sarin, 2005^75^ | 3.89 (1.20; 12.69) | Interferon alfa 2b+lamivudine vs. lamivudine resulted in increase rates of HBeAg loss in patients with baseline HBV DNA >107 copies/mL
HBeAg loss and seroconversion | Interferon alfa 2b+lamivudine vs. lamivudine | 52/24 | 1/75 | Sarin, 2005^75^ | 4.87 (1.14; 20.74) | Interferon alfa 2b+lamivudine vs. lamivudine resulted in increase rates of HBeAg seroconversion and HBV DNA loss in patients with baseline HBV DNA >107 copies/mL
Viral breakthrough -reappearance of serum HBV-DNA | Interferon alfa 2b+lamivudine vs. lamivudine | 176/192 | 1/83 | Jang, 2004^72^ | Random association with baseline HBV DNA levels (1 unit increase)
Adjusted for treatment status odds ratio of HBeAg seroconversion, HBV DNA loss and ALT normalization in HBeAg (+) patients. In HBeAg (-) patients: loss of HBV DNA, ALT normalization | Peginterferon alfa-2a+lamivudine vs. lamivudine | 9/6 | 1/140 | Cindoruk, 2007^97^ | 1.05 (0.13; 8.14) | Baseline mean viral load (copy/mL)was not associated with sustained response to the therapy
Sustained combined response: ALT normalization and an HBV DNA loss | Peginterferon alfa-2a+lamivudine vs. lamivudine | 48/24 | 1/76 | Bonino, 2007^93^ | 2.24 (1.31; 3.83) | Peginterferon alfa-2a+lamivudine vs. lamivudine increased sustained response among patients with baseline HBV DNA <6.12 log10 copies/ml
Sustained combined response: ALT normalization and an HBV DNA loss | Peginterferon alfa-2a+lamivudine vs. lamivudine | 48/24 | 1/76 | Bonino, 2007^93^ | 1.78 (1.11; 2.84) | Peginterferon alfa-2a+lamivudine vs. lamivudine increased sustained response among patients with baseline HBV DNA >6.12–8.42 log 10 copies/ml
1.37 (0.67; 2.80) | Peginterferon alfa-2a+lamivudine vs. lamivudine did not increase sustained response among patients with baseline HBV DNA >8.42 log 10 copies/ml
HBeAg seroconversion | Peginterferon alfa-2a+lamivudine vs. lamivudine | 48/24 | 1/543 | Lau, 2005^96^ | 0.84 (0.47; 1.48) | Peginterferon alfa-2a+lamivudine vs. lamivudine did not increase HBeAg seroconversion among patients with baseline HBV DNA levels ≤9.07 (log copies/ml)
HBeAg seroconversion | Peginterferon alfa-2a+lamivudine vs. lamivudine | 48/24 | 1/543 | Lau, 2005^96^ | 1.91 (1.16; 3.15) | Peginterferon alfa-2a+lamivudine vs. lamivudine increased HBeAg seroconversion among patients baseline HBV DNA levels >9.07–10.26 (log copies/ml)
2.01 (0.82; 4.90) | Peginterferon alfa-2a+lamivudine vs. lamivudine did not increase HBeAg seroconversion among patients with baseline HBV DNA levels >10.26 (log copies/ml)
HBeAg seroconversion | Peginterferon alfa-2a+lamivudine vs. peginterferon alfa-2a | 48/24 | 1/542 | Lau, 2005^96^ | 0.54 (0.32; 0.91) | The rates of HBeAg seroconversion were lower after peginterferon alfa-2a+lamivudine vs. peginterferon alfa-2a among the patients with baseline HBV DNA levels ≤9.07 (log copies/ml)
HBeAg seroconversion | Peginterferon alfa-2a+lamivudine vs. peginterferon alfa-2a | 48/24 | 1/542 | Lau, 2005^96^ | 1.03 (0.68; 1.54) | Random differences among patients with baseline HBV DNA levels >9.07–10.26 (log copies/ml)
1.27 (0.59; 2.75) | Random differences among patients with baseline HBV DNA levels>10.26 (log copies/ml)
Sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | Peginterferon alfa-2a+placebo vs. lamivudine | 48/24 | 1/96 | Bonino, 2007^93^ | 1.27 (0.71; 2.30) | Random differences among patients with baseline HBV DNA <6.12 log10 copies/ml
Sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | Peginterferon alfa-2a+placebo vs. lamivudine | 48/24 | 1/96 | Bonino, 2007^93^ | 3.87 (2.55; 5.88) | Peginterferon alfa-2a+ placebo vs. lamivudine increased the rates of sustained response among patients with baseline HBV DNA >6.12–8.42 log 10 copies/ml
1.80 (0.91; 3.57) | Random differences among patients with baseline HBV DNA >8.42 log 10 copies/ml
HBeAg seroconversion | Peginterferon alfa-2a+placebo vs. lamivudine | 48/24 | 1/543 | Lau, 2005^96^ | 1.55 (0.95; 2.51) | Random differences among patients with baseline HBV DNA levels ≤9.07 (log copies/ml)
HBeAg seroconversion | Peginterferon alfa-2a+placebo vs. lamivudine | 48/24 | 1/543 | Lau, 2005^96^ | 1.86 (1.13; 3.08) | Peginterferon alfa-2a+placebo vs. lamivudine increased rates of HBeAg seroconversion among patients with baseline HBV DNA levels >9.07–10.26 (log copies/ml)
1.58 (0.62; 4.01) | Random differences among patients with baseline HBV DNA levels >10.26 (log copies/ml)
Adjusted odds ratios of sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | Peginterferon alfa-2a vs. lamivudine | 48/24 | 1/1036 | Bonino, 2007^93^ | 1.06 (0.93; 1.21) | Baseline HBV DNA (Log10) was not associated with sustained response to therapy
Adjusted for treatment allocation, hepatitis B virus (HBV) genotype, baseline ALT odds ratio of persistent HBeAg loss | Peginterferon alfa-2b+lamivudine vs. lamivudine | 60/0 | 1/100 | Chan, 2006^108^ | 0.70 (0.38; 1.30) | Baseline HBV DNA (log10) was not associated with sustained response to therapy
Adjusted for treatment allocation, HBV DNA genotype, IL-1b-511 polymorphism, baseline ALT odds ratio of persistent HBeAg loss and had less than 2 occasions with HBV DNA <100,000 copies/mL | Peginterferon alfa-2b+lamivudine vs. lamivudine | 60/0 | 1/100 | Chan, 2006^108^ | 0.65 (0.35; 1.20) | Baseline HBV DNA (log10) was not associated with sustained response to therapy
Adjusted odds ratio of sustained HBeAg loss | Peginterferon alfa-2b+lamivudine vs. peginterferon alfa-2b | 52/0 | 1/307 | Janssen, 2005^99^ | 1.60 (1.30; 1.80) | Peginterferon alfa-2b+lamivudine vs. peginterferon alfa-2b increased the rates of HBeAg loss among patients with low baseline viral load
Multivariate adjusted odds ratio of sustained combined response: HBeAg-negative, HBV DNA <5 log10 copies/mL, and normal ALT level | Peginterferon alfa-2b vs. interferon alfa 2b | 24/0 | 1/230 | Zhao, 2007^109^ | 0.53 (0.22; 1.28) | Random difference among patients with baseline HBV DNA >8.1 vs. <8.1 log 10 copies/mL
Genotype, outcomes at followup off treatment
Adjusted for age, gender, baseline ALT, HBV DNA, and histology, precore G1896A mutation, core promoter A1762T, G1764A, and treatment with interferon with and without prednisone pretreatment odds ratios of sustained HBV DNA loss | Interferon alfa 2b+corticosteroid vs. interferon alfa 2b | 24/0 | 1/115 | Wai, 2002^65^ | 1.28 (1.06; 1.42) | Patients with HBV genotype B vs. C had better sustained response to the therapy
1/68 | Wai, 2002^65^ | 1.47 (1.18; 1.82) | Patients with HBV genotype B vs. C and elevated baseline ALT had better sustained response to the therapy
Sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | Peginterferon alfa-2a+lamivudine vs. lamivudine | 48/24 | 1/126 | Bonino, 2007^93^ | 2.09 (1.29; 3.40) - C | Peginterferon alfa-2a+lamivudine vs. lamivudine increased the rates of sustained response among patients with genotype C or genotype D
3.33 (1.53; 7.27) - D
HBeAg seroconversion | Peginterferon alfa-2a+lamivudine vs. lamivudine | 48/24 | 1/543 | Lau, 2005^96^ | 1.34 (0.30; 5.92) | Random difference among patients with HBV genotype A
HBeAg seroconversion | Peginterferon alfa-2a+lamivudine vs. lamivudine | 48/24 | 1/543 | Lau, 2005^96^ | 1.42 (0.78; 2.58) | Random difference among patients with HBV genotype B
HBeAg seroconversion | Peginterferon alfa-2a+lamivudine vs. lamivudine | 48/24 | 1/543 | Lau, 2005^96^ | 1.49 (0.96; 2.31) | Random difference among patients with HBV genotype C
0.67 (0.11; 3.97) | Random difference among patients with HBV genotype D
HBeAg seroconversion | Peginterferon alfa-2a+lamivudine vs. peginterferon alfa-2a | 48/24 | 1/542 | Lau, 2005^96^ | 0.33 (0.11; 1.02) | Random difference among patients with HBV genotype A
HBeAg seroconversion | Peginterferon alfa-2a+lamivudine vs. peginterferon alfa-2a | 48/24 | 1/542 | Lau, 2005^96^ | 1.04 (0.60; 1.80) | Random difference among patients with HBV genotype B
HBeAg seroconversion | Peginterferon alfa-2a+lamivudine vs. peginterferon alfa-2a | 48/24 | 1/542 | Lau, 2005^96^ | 0.86 (0.59; 1.25) | Random difference among patients with HBV genotype C
1.00 (0.14; 7.05) | Random difference among patients with HBV genotype D
Sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | Peginterferon alfa-2a+placebo vs. lamivudine | 48/24 | 1/19 | Bonino, 2007^93^ | 2.18 (0.27; 17.32) | Random differences among patients with genotype A
Sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | Peginterferon alfa-2a+placebo vs. lamivudine | 48/24 | 1/19 | Bonino, 2007^93^ | 1.14 (0.70; 1.85) | Random differences among patients with genotype B
Sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | Peginterferon alfa-2a+placebo vs. lamivudine | 48/24 | 1/19 | Bonino, 2007^93^ | 2.22 (1.36; 3.63) | Peginterferon alfa-2a+placebo vs. lamivudine increased the rates of sustained response among patients with genotype C
1.47 (0.59; 3.69) | Random differences among patients with genotype D
HBeAg seroconversion | Peginterferon alfa-2a+placebo vs. lamivudine | 48/24 | 1/543 | Lau, 2005^96^ | 4.01 (1.15; 14.07) | Peginterferon alfa-2a+placebo vs. lamivudine increased the rates of e Ag seroconversion among patients with HBV genotype A
HBeAg seroconversion | Peginterferon alfa-2a+placebo vs. lamivudine | 48/24 | 1/543 | Lau, 2005^96^ | 1.36 (0.74; 2.48) | Random differences among patients with HBV genotype B
HBeAg seroconversion | Peginterferon alfa-2a+placebo vs. lamivudine | 48/24 | 1/543 | Lau, 2005^96^ | 1.73 (1.13; 2.65) | Peginterferon alfa-2a+placebo vs. lamivudine increased the rates of e Ag seroconversion among patients with HBV genotype C
0.67 (0.11; 3.97) | Random differences among patients with HBV genotype D
Adjusted odds ratios of sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | Peginterferon alfa-2a vs. lamivudine | 48/24 | 1/1036 | Bonino, 2007^93^ | 2.58 (0.73; 9.20) | Random difference between genotypes (A vs. D)
Adjusted odds ratios of sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | Peginterferon alfa-2a vs. lamivudine | 48/24 | 1/1036 | Bonino, 2007^93^ | 3.69 (1.54; 8.79) | Rates of sustained response were higher among patients with genotype B vs. D
5.46 (2.46; 12.10) | Rates of sustained response were higher among patients with genotype C vs. D
Adjusted for treatment allocation, HBV genotype, baseline ALT, and log HBV DNA odds ratio of persistent HBeAg loss at any time up to week 76 of post-treatment | Peginterferon alfa-2b+lamivudine vs. lamivudine | 60/24 | 1/100 | Chan, 2006^108^ | 10.37 (1.11; 96.96) | Rates of response were higher among patients with interleukin (IL)-1b-511 baseline genotype C/T vs. C/C
Adjusted for treatment allocation, HBV genotype, baseline ALT, and log HBV DNA odds ratio of persistent HBeAg loss at any time up to week 76 of post-treatment | Peginterferon alfa-2b+lamivudine vs. lamivudine | 60/24 | 1/100 | Chan, 2006^108^ | Random differences in patients with genotype C vs. B
Adjusted for treatment allocation, HBV genotype, baseline ALT, and log HBV DNA odds ratio of persistent HBeAg loss at any time up to week 76 of post-treatment | Peginterferon alfa-2b+lamivudine vs. lamivudine | 60/24 | 1/100 | Chan, 2006^108^ | Random differences in patients with Haplotype -511/-31 of interleukin (IL)-1b C-T vs. T-C
Adjusted for treatment allocation, HBV genotype, baseline ALT, and log HBV DNA odds ratio of persistent HBeAg loss at any time up to week 76 of post-treatment | Peginterferon alfa-2b+lamivudine vs. lamivudine | 60/24 | 1/100 | Chan, 2006^108^ | Random differences in patients with interleukin (IL)-1b-511 baseline genotype T/T vs. C/C
Adjusted for treatment allocation, HBV genotype, baseline ALT, and log HBV DNA odds ratio of persistent HBeAg loss at any time up to week 76 of post-treatment | Peginterferon alfa-2b+lamivudine vs. lamivudine | 60/24 | 1/100 | Chan, 2006^108^ | Random differences in patients with interleukin (IL)-1b-31 baseline genotype C/T vs. T/T or C/C vs. T/T
Adjusted for treatment allocation, HBV genotype, baseline ALT, and log HBV DNA odds ratio of persistent HBeAg loss at any time up to week 76 of post-treatment | Peginterferon alfa-2b+lamivudine vs. lamivudine | 60/24 | 1/100 | Chan, 2006^108^ | Random differences in patients with IL-1 receptor antagonist genotype IL-1RN 1/2 vs. 1/1
Adjusted for treatment allocation, HBV genotype, baseline ALT, and log HBV DNA odds ratio of persistent HBeAg loss at any time up to week 76 of post-treatment | Peginterferon alfa-2b+lamivudine vs. lamivudine | 60/24 | 1/100 | Chan, 2006^108^ | Random differences in patients with interleukin (IL)-1b-511 baseline genotype C/T and T/T vs. C/C
Random differences in patients with interleukin (IL)-1b-31 baseline genotype C/T and C/C vs. T/T
Adjusted relative risk of HBeAg seroconversion and HBV DNA <10,000 copies/ml. | Peginterferon alfa-2b+lamivudine vs. peginterferon alfa-2b | 52/26 | 1/307 | Buster, 2007^100^ | 11.30 (1.38; 92.57) | Adjusted rates of sustained response were higher among patients with genotype A vs. C
Adjusted relative risk of HBeAg seroconversion and HBV DNA <10,000 copies/ml. | Peginterferon alfa-2b+lamivudine vs. peginterferon alfa-2b | 52/26 | 1/307 | Buster, 2007^100^ | 4.28 (1.39; 13.21) | Adjusted rates of sustained response were higher among patients with genotype A vs. D
Adjusted relative risk of HBeAg seroconversion and HBV DNA <10,000 copies/ml. | Peginterferon alfa-2b+lamivudine vs. peginterferon alfa-2b | 52/26 | 1/307 | Buster, 2007^100^ | 12.13 (1.24; 118.30) | Adjusted rates of sustained response were higher among patients with genotype B vs. C
4.59 (1.14; 18.43) | Adjusted rates of sustained response were higher among patients with genotype B vs. D
Adjusted odds ratio of sustained HBeAg loss | Peginterferon alfa-2b+lamivudine vs. peginterferon alfa-2b | 52/26 | 1/307 | Janssen, 2005^99^ | 2.40 (1.30; 4.60) | Adjusted rates of sustained response were higher among patients with HBV genotype A vs. D
Adjusted odds ratio of sustained HBeAg loss | Peginterferon alfa-2b+lamivudine vs. peginterferon alfa-2b | 52/26 | 1/307 | Janssen, 2005^99^ | 3.60 (1.40; 8.90) | Adjusted rates of sustained response were higher among patients with HBV genotype A vs. C
2.20 (0.70; 7.00) | Random difference among patients with HBV genotype B vs. C
Multivariate adjusted odds ratio of sustained HBeAg loss, HBV DNA <5 log 10 copies/mL, and normal ALT level | Peginterferon alfa-2b vs. interferon alfa 2b | 24/24 | 0/250 | Zhao, 2007^109^ | 0.19 (0.08; 0.46) | RR, response was lower among patients with genotype C vs. B
Previous treatment, outcomes at followup off treatment
HBeAg seroconversion | Peginterferon alfa-2a+lamivudine vs. lamivudine | 48/24 | 1/543 | Lau, 2005^96^ | 1.52 (1.08; 2.12) | Rates of HBeAg seroconversion were higher among patients with no previous exposure to lamivudine
Random differences among those with previous LAM or Interferon therapy
HBeAg seroconversion | Peginterferon alfa-2a+lamivudine vs. peginterferon alfa-2a | 48/24 | 1/542 | Lau, 2005^96^ | Random differences among all patients with and without previous treatment
HBeAg seroconversion | Peginterferon alfa-2a+placebo vs. lamivudine | 48/24 | 1/543 | Lau, 2005^96^ | 1.58 (1.11; 2.23) | Peginterferon alfa-2a+placebo vs. lamivudine increased the rates of HBeAg seroconversion among patients with no previous anti-HBV therapy
HBeAg seroconversion | Peginterferon alfa-2a+placebo vs. lamivudine | 48/24 | 1/543 | Lau, 2005^96^ | 1.43 (0.55; 3.71) | Random differences among patients with previous treatment: LAM
HBeAg seroconversion | Peginterferon alfa-2a+placebo vs. lamivudine | 48/24 | 1/543 | Lau, 2005^96^ | 1.72 (1.24; 2.38) | Peginterferon alfa-2a+placebo vs. lamivudine increased the rates of HBeAg seroconversion among patients with no previous exposure to lamivudine
HBeAg seroconversion | Peginterferon alfa-2a+placebo vs. lamivudine | 48/24 | 1/543 | Lau, 2005^96^ | 3.26 (1.08; 9.88) | Peginterferon alfa-2a+placebo vs. lamivudine increased the rates of HBeAg seroconversion among patients with previous treatment: IFN
1.55 (1.12; 2.14) | Peginterferon alfa-2a+placebo vs. lamivudine increased the rates of HBeAg seroconversion among patients with no previous exposure to conventional interferon
HBeAg loss | Peginterferon alfa-2b+lamivudine vs. peginterferon alfa-2b | 52/26 | 2/307 | Janssen, 2005^99^ | 2.20 (1.10; 4.50) | Peginterferon alfa-2b+lamivudine vs. peginterferon alfa-2b increased the rates of HBeAg loss among patients without previous interferon therapy
HBeAg loss | Peginterferon alfa-2b+lamivudine vs. peginterferon alfa-2b | 52/26 | Flink, 2006^102^ | 0.94 (0.63; 1.40) | Random differences among naïve to any treatments patients
1/307 | Flink, 2006^102^ | Random differences among patients with previous IFN, LAM, and combined therapy
HBV DNA loss, normalization of ALT | | | | | Random differences among patients naïve to any antiviral treatment

At 24 weeks of followup off the administration of interferon alfa-2b with corticosteroid pretreatment, compared to interferon alfa-2b alone, HBV DNA loss was more frequent among patients with elevated baseline ALT (RR 1.22, 95 percent CI 1.05; 1.42)^65^ (Appendix E Tables 9 and 10). Adjusted odds of sustained virologic response to interferon alfa-2b combined with lamivudine compared to lamivudine were higher in patients with baseline ALT >150UL (RR 3.12, 95 percent CI 1.43; 6.82).^63^ Sustained HBeAg loss or seroconversion after interferon alfa-2b combined with lamivudine compared to lamivudine alone was higher among patients with elevated ALT with nonsignificant differences among those with baseline ALT <1 ULN or 1–2 ULN.^64^ Sustained response to peginterferon alfa-2a combined with lamivudine compared to lamivudine alone was greater per increase in one unit (U/L) in baseline ALT (RR 10.32, 95 percent CI 9.71; 10.97).^97^ Sustained HBeAg seroconversion after peginterferon alfa-2a combined with lamivudine compared to lamivudine alone was greater among patients with baseline ALT >5 ULN (RR 1.93, 95 percent CI 1.01; 3.69) with random differences among those with baseline ALT <2 or 2–5 ULN.^96^ However, several studies reported no association between dose response increase in baseline ALT and sustained response to peginterferon alfa-2a compared to lamivudine^96^ or peginterferon alfa-2b combined with lamivudine versus lamivudine.^108^

In conclusion, the low level of evidence indicated that treatment induced effects on disease progression and liver decompensation do not vary by baseline ALT levels. The low level of evidence indicated that treatment induced HBeAg clearance and seroconversion, HBeAg loss, or virologic loss vary by baseline liver function with inconsistent across the studies evidence of better response among patients with elevated baseline ALT.

Genotype of HBV DNA (eight studies, two antiviral agents, peginterferon and lamivudine used as mono or combination therapy) (Appendix E Tables 9 and 10). The effects of antiviral drugs on intermediary outcomes among patients with different HBV DNA genotype have been evaluated at the end of treatments^93^ and at followup off the therapies (seven studies).^65,^ ^93,^ ^96,^ ^99,^ ^100,^ ^108,^ ^109^ (Appendix E Tables 9 and 10). Adjusted odds ratios of ALT normalization and reduction of HBV DNA level <20,000 copies/ml after 48 weeks of peginterferon alfa-2a administration compared to lamivudine were significantly greater among patients with genotype B versus D (OR 2.31, 95 percent CI 1.30; 4.20) and genotype C versus D (OR 2.90, 95 percent CI 1.70; 5.00). Patients with genotype A had lower adjusted odds of response defined as ALT normalization and an HBV DNA level of <20,000 copies/ml compared to patients with genotype C (OR 0.33, 95 percent CI 0.10; 0.90).^93^ No differences in treatment effects were found between patients with genotype A versus B, A versus D, or B versus C.^93^

Off treatment response to the same treatments also differed with greater adjusted odds of success among patients with genotype B versus D (OR 3.69, 95 percent CI 1.54; 8.79) and with genotype C versus D (OR 5.46, 95 percent CI 2.46; 12.10).^93^ Patients with genotype B HBV DNA experienced sustained clearance of serum HBV DNA after interferon alfa-2b combined with steroid pretreatment compared to interferon alfa-2b alone more often than those with genotype C (adjusted OR 1.28, 95 percent CI 1.06; 1.42).^65^ One RCT reported no significant differences in sustained HBeAg seroconversion after peginterferon alfa-2a combined with lamivudine compared to peginterferon alfa-2a or lamivudine alone among all genotypes of HBV DNA.^96^

In conclusion, the low level of evidence indicated that treatment induced ALT normalization and HBV DNA clearance or HBeAg seroconversion vary by HBV DNA genotype with better response among patients with genotype B and C. There was no evidence for clinical outcomes.

Previous treatment status (seven studies, four antiviral agents, peginterferon, interferon, adefovir, and lamivudine used as mono or combination therapy) (Appendix E Tables 9 and 10). Off-treatment rates of HBeAg seroconversion after administration of peginterferon alfa-2a plus lamivudine compared to lamivudine were higher among patients with no previous exposure to lamivudine (RR 1.52, 95 percent CI 1.08; 2.12)^96^ with no significant differences among previously treated patients. Off-treatment HBeAg seroconversion was better after monotherapy with peginterferon alfa-2a compared to lamivudine in naïve to lamivudine patients (RR 1.72, 95 percent CI 1.24; 2.38).^96^ Random differences were observed in patients previously treated with lamivudine.^96^

Five RCTs enrolled lamivudine resistant patients,^118,^ ^119,^ ^124,^ ^125,^ ^141^ and one enrolled interferon resistant patients.^92^ Adefovir combined with lamivudine for 48 weeks did not result in better outcomes, including rates of HBV DNA reduction to less than <2,000 copies/ml and ALT normalization compared to adefovir alone in lamivudine resistant patients.^118^ Adefovir combined with lamivudine compared to lamivudine alone resulted in greater rates of ALT normalization (ARD 0.45, 95 percent CI 0.21; 0.69) and HBV DNA clearance (ARD 0.35, 95 percent CI 0.13; 0.57) in patients with lamivudine-resistant CHB with random differences in HBeAg clearance or seroconversion;^119^ however, the same trial reported that combined treatment did not improve outcomes compared to adefovir alone.^119^ Adefovir monotherapy improved ALT normalization compared to lamivudine alone (ARD after lamivudine versus adefovir -0.42, 9 percent CI -0.67; -0.18) with random differences in HBeAg clearance and seroconversion.^119^ The BEHoLD Study Group enrolled 182 lamivudine-refractory patients to start entecavir administration or continued on lamivudine for 48 weeks.^124^ Mortality after 48 weeks of therapy and at 28 weeks of followup did not differ among treatment groups.^124^ The largest dose of entecavir (1mg/day) increased HBV DNA loss in combination with normalization of ALT level at 48 weeks of the treatment (ARD 0.67, 95 percent CI 0.41; 0.92).^124^ Viral clearance (HBV DNA <400 copies/mL) or normalization of ALT levels was greater after all doses of entecavir compared to lamivudine.^124^ Entecavir increased the rates of HBV DNA and HBeAg clearance and normalization of ALT level in lamivudine-refractory, HBeAg-positive CHB patients compared to lamivudine, the effects were significant after 1mg/day (ARD 0.67, 95 percent CI 0.41; 0.92) or 0.5mg/day (ARD 0.40, 95 percent CI 0.14; 0.66).^125^ The BEHoLD Study Group enrolled HBeAg-positive patients with persistent viremia or documented YMDD mutations after previous lamivudine therapy that were randomized to switch to entecavir 1 mg daily or continue lamivudine for a minimum of 52 weeks.^125^ Entecavir increased rates of HBV DNA clearance and ALT normalization (ARD 0.50, 95 percent CI 0.42; 0.59), HBV DNA loss (<300 copies/mL by PCR) (ARD 0.18, 95 percent CI 0.11; 0.25), and HBeAg clearance (ARD 0.06, 95 percent CI 0.01; 0.12).^125^ Improvement in necroinflammatory Knodell score (ARD 0.26, 95 percent CI 0.16; 0.37) and Ishak fibrosis scores (ARD 0.17, 95 percent CI 0.07; 0.26) was greater after entecavir therapy.^125^ Discontinuation of lamivudine in 74 patients with lamivudine-resistant mutants resulted in the same rates of hepatic decompensation, ALT normalization, or HBeAg seroconversion compared to continuous administration of lamivudine.^141^ A combination of interferon alfa-2b with lamivudine in 20 patients who failed previous interferon therapy did not improve HBV DNA or HBeAg clearance and ALT normalization.^92^

In conclusion, the low to moderate level of evidence indicated that treatment induced HBeAg seroconversion, ALT normalization, HBV DNA clearance, and improved histology are greater in patients naïve to antiviral medications. Entecavir improved virological and biochemical outcomes in lamivudine resistant patients without differences in mortality.

YMDD mutation (two studies, one antiviral agent used as monotherapy) (Appendix E Tables 9 and 10). One study examined the effect of 48 week lamivudine treatment versus placebo on liver histology in Chinese patients with and without YMDD mutations.^130^ The authors reported improvement in necroinflammatory but not in fibrosis scores in patients with and without mutations; however, lamivudine improved the outcome of “worsened histology” only among patients without YMDD mutation (ARD 0.15, 95 percent CI 0.04; 0.54) (there was no protective effect in patients with YMDD mutations).^130^ A study of discontinuing lamivudine in lamivudine resistant patients reported no association between YMDD mutations and hepatic decompensation, defined as change in the Child-Turcotte-Pugh score of two or more points after adjustments for ALT, baseline viral load, sex, YMDD variant, platelet, bilirubin, and albumin.^141^

In conclusion, low level of evidence indicated that treatment induced changes in liver histology are associated with baseline YMDD mutation. There was no evidence that this mutation was associated with differences in clinical outcomes.

Outcomes across studies with different patient populations. We analyzed the differences in off treatment outcomes across the studies that included different proportions of patients with HBeAg-positive status, baseline cirrhosis, and previous antiviral treatments. Clinical outcomes were not reported. Interferon alfa-2b combined with lamivudine compared to interferon alfa-2b alone increased HBV DNA clearance in studies that enrolled treatment naïve patients with random differences in the studies of previously treated patients (Appendix E. Figure 22).^62,^ ^68,^ ^69,^ ^72,^ ^74,^ ^75,^ ^84,^ ^87^ However, the effects of interferon alfa-2b compared to no treatment or after combined interferon alfa-2b+lamivudine compared to lamivudine alone on HBV DNA loss did not show a clear pattern according to patient populations across the studies. Sustained HBeAg clearance after compared treatments was the same across the studies (Appendix E. Figure 23).^62^–^64,^ ^67,^ ^80,^ ^83,^ ^87,^ ^88,^ ^91,^ ^98,^ ^99,^ ^136^ Sustained HBeAg seroconversion was greater after interferon alfa-2b combined with lamivudine versus lamivudine monotherapy in one study;^63^ however, another study^67^ that assessed interferon nonresponders and a European trial of previously untreated patients reported opposite association with better effects from lamivudine monotherapy therapy. ^67^ Sustained ALT normalization after compared treatments was the same across the studies (Appendix E. Figure 24).^10,^ ^62,^ ^63,^ ^72,^ ^74^–^76,^ ^84,^ ^87,^ ^95,^ ^96,^ ^113^

Summary. There is no high quality evidence that clinical outcomes of all-cause or disease specific mortality, hepatocellular carcinoma or hepatic decompensation are improved with currently approved and investigated therapeutic strategies (i.e., drug, dose, duration, patient population). Changes in biochemical, virologic, and histologic measures at the end of treatment or off treatment are frequently used to assess therapeutic effectiveness. However, these measures have not been demonstrated to be accurate surrogates for determining long-term clinical outcomes due to treatments. All treatments are associated with harms and immediate pharmaceutical costs, though most drugs are well tolerated and adverse effects are relatively mild. Therefore, it is difficult to determine what patients would derive clinical benefit. There is low evidence that treatment improves HBsAg clearance and measures of hepatitis resolution. This is beneficial because loss of HBsAg likely eliminates viral transmission to noninfected individuals and defines resolved hepatitis B. Individuals who are inactive carriers also have persistence of HBsAg positivity and a very favorable long-term prognosis. Therefore, for these individuals treatment is unlikely to provide a small benefit beyond risk of transmission.

### EPC Question 3b. Is there evidence that specific subpopulations do not require treatment for hepatitis B (i.e., that the surrogate and/or clinical outcomes are equivalent or superior when not exposed to treatment?)

Specific subpopulations would not require treatment if their clinical outcomes (and possibly validly defined surrogate measures) were equivalent or superior to similar populations not receiving treatment. Situations could result from: (a) extremely favorable long-term natural history/prognosis of various forms of hepatitis B (e.g., chronic carrier status); (b) patient characteristics (e.g., advanced age, comorbidities, poor compliance) that result in short life expectancy that markedly lowers the individual's risk of hepatitis B related complications largely independent of hepatitis B characteristics or reduces treatment effectiveness; (c) ineffective therapy or disease characteristics that result in resistance to otherwise effective therapies (e.g., mutations); or (d) harms of therapy that outweigh benefits. Findings reported for EPC question 1 outline the natural history of CHB reporting on the long-term risks of hepatocellular carcinoma, cirrhosis, and death according to patient, hepatitis and comorbidity factors.

Here we review the evidence of no treatment benefit on biological, biochemical, or histological outcomes from antiviral drugs compared to placebo or symptomatic therapy without antiviral medications. Clinicians, investigators, and patients can use this information to decide in which specific patient subpopulations treatment regimens have shown lack of effectiveness. Interferon alfa-2b compared to no treatment did not increase the sustained rates of resolved hepatitis including HBV DNA, HBeAg, and HBsAg clearance and ALT normalization in patients with HBeAg-positive hepatitis.^82,^ ^89^ Interferon alfa-2b did not improve histology in HBeAg-negative^91^ or HBeAg-positive patients.^83^ Two RCTs, including the American Hepatitis Interventional Therapy Group^84^ and a German study^69^ of HBeAg-positive patients showed no significant sustained HBV DNA clearance after prednisone withdrawal followed by administration of interferon alfa-2b compared to no treatment. Interferon alfa-2b with prednisone priming failed to increase sustained HBV DNA, HBeAg, and HBsAg clearance in Chinese patients. ^73^ Interferon alfa-2b combined with lamivudine compared to placebo failed to increase HBeAg clearance or sustained HBeAg seroconversion in patients who were participating in four lamivudine-controlled Phase III trials^64^ and in nonresponders to the previous interferon therapy (International Lamivudine Investigator Group.)^67^ The International Lamivudine Investigator Group also reported that interferon nonresponders did not experience sustained HBsAg clearance and improvement in histological scores after combined therapy with interferon alfa-2b and lamivudine.^67^

Lamivudine compared to placebo failed to maintain sustained HBeAg seroconversion in interferon non responders^67^ and in treatment naïve patients with CHB.^136^ Patients with HBeAg-positive^67,^ ^136^ and HBeAg-negative^139^ hepatitis B did not experience sustained HBsAg loss after lamivudine administration compared to placebo. Patients with HBeAg-negative CHB also did not have better rates of sustained HBV DNA clearance and ALT normalization after two years of lamivudine administration.^139^

In conclusion, the low level of evidence suggested that individuals who failed previous interferon alfa-2b therapy did not benefit after combined interferon and lamivudine treatment. Patients with HBeAg did not experience sustained HBeAg seroconversion after interferon alfa-2b combined with lamivudine.

High risk of serious adverse events or noncompliance. We next assessed whether certain patient or hepatitis characteristics were associated with unacceptably high risk of serious adverse events or noncompliance. Little data were available to assess this issue.

Adefovir. Administration of adefovir compared to placebo^10,^ ^110,^ ^112,^ ^113,^ ^115,^ ^116^ was well tolerated in HBeAg-positive^112,^ ^113^ and HBeAg-negative patients.^10,^ ^110^ Discontinuation of therapy due to adverse events did not differ between administration of adefovir and placebo in HBeAg-positive patients.^112,^ ^113^ The Adefovir Dipivoxil 438 Study Group found no differences in the rates of any or serious adverse events compared to placebo in HBeAg-negative^110^ and HBeAg-positive patients.^112^ Previously treated patients and those with baseline cirrhosis were not at greater risk after adefovir therapy compared to placebo. Lamivudine-resistant HBeAg-positive patients experienced less insomnia and rash (ARD -0.21, 95 percent CI -0.40; -0.02) and increase in ALT (ARD -0.32, 95 percent CI -0.56; -0.08) after adding adefovir to lamivudine therapy compared to lamivudine or adefovir alone^119^ with random differences in other examined adverse effects. Patients with YMDD mutant tolerated well addition of adefovir to ongoing lamivudine therapy.^117^

In conclusion, adefovir alone was well tolerated in patients with CHB. Lamivudine resistant patients experienced less frequent adverse events after combined therapy of adefovir and lamivudine.

Entecavir. The rates of any or serious adverse effects did not differ after administration of entecavir compared to lamivudine.^121^–^126^ Discontinuation rates due to adverse events were less after administration of entecavir (ARD -0.02, 95 percent CI -0.04; -0.01) in HBeAg-positive naïve to antiviral drugs patients^122^ and in lamivudine-resistant, HBeAg-positive patients (ARD -0.05, 95 percent CI -0.10; -0.01).^125^

In conclusion, entecavir was better tolerated compared to lamivudine in examined patient populations, though serious adverse effects were similar.

Interferon alfa-2b. The European Concerted Action on Viral Hepatitis (EUROHEP)^61^ reported increased rates of dose reduction due to depression, fatigue, hair loss, and headache after interferon alfa-2b compared to placebo (11 versus 0 percent) in HBeAg-positive patients with CHB. Patients with HBeAg-negative baseline status discontinued interferon administration due to adverse effects more often compared to placebo (24 versus 0 percent).^91^ Reduction in dose of interferon alfa-2b due to adverse effects was reported in HBeAg-positive American patients (34 versus 0 percent after placebo).^87^ Other adverse effects were comparable after administration of interferon compared to placebo.^61,^ ^69,^ ^82,^ ^84,^ ^87,^ ^89,^ ^91^

Combined therapy with interferon alfa-2b and lamivudine. The International Lamivudine Investigator Group included HBeAg-positive patients with CHB who had failed previous interferon therapy^67^ and reported that combined therapy with interferon alfa-2b and lamivudine compared to placebo increased the rates of malaise/fatigue (95 versus 32 percent), fever (95 versus 0 percent), headache (76 versus 23 percent), nausea/vomiting (59 versus 20 percent), hair loss/alopecia (48 versus 4 percent), muscle pain (46 versus 9 percent), viral respiratory infections (35 versus 0 percent), feeding problems (30 versus 4 percent), depression (27 versus 4 percent), decreased white blood cells (WBCs) (25 versus 0 percent), rheumatism (25 versus 4 percent), diarrhea (21 versus 0 percent), and musculoskeletal pain (16 versus 4 percent).^67^

In conclusion, HBeAg-positive patients tolerant to interferon alfa-2b experienced frequent adverse events after adding of lamivudine to continued interferon alfa-2b.

Monotherapy with interferon alfa-2b compared to lamivudine in treatment naïve, HBeAg-positive, predominantly Caucasian patients increased the rates of malaise and fatigue (100 versus 42 percent), arthralgia (33 versus 5 percent), anorexia (47 versus 5 percent), dizziness (27 versus 10 percent), nausea and vomiting (49 versus 23 percent), fever/chills (61 versus 7 percent), hair loss and alopecia (30 versus 10 percent), histological relapse (increase in Knodell score by at least two points) (25 versus 9 percent), headache (67 versus 32 percent), and muscle pain (57 versus 13 percent).^62^ Adverse effects did not cause discontinuation of interferon alfa-2b more often than lamivudine.^62^

Reduction in dose because of severe side effects,^80,^ ^88^ virological relapse,^84,^ ^85^ or unchanged HBV DNA load^69^ after interferon alfa-2b following prednisone withdrawal were the same compared to interferon alfa-2b alone.

Interferon alfa-2b combined with lamivudine compared to interferon alfa-2b alone^62,^ ^68^ increased the rates of dry mouth (ARD 0.57, 95 percent CI 0.33; 0.81) in a Turkish RCT of HBeAg-positive previously untreated patients^68^ and the rates of headache (ARD 0.26, 95 percent CI 0.14; 0.39) in predominantly Caucasian patients naïve to antiviral drugs.^62^ Combined treatments reduced the rates of malaise and fatigue (87 versus 100 percent), arthralgia (12 versus 33 percent), dizziness (12 versus 27 percent), and hepatitis flares (0 versus 11 percent);^62^ however, the rates of adverse effects were higher after combined therapy when compared to lamivudine alone.^62,^ ^63,^ ^67,^ ^71,^ ^72,^ ^74^–^77,^ ^79^ Patients experienced influenza like symptoms more frequently (pooled ARD 0.47, 95 percent CI 0.36; 0.58),^63,^ ^75^ viral respiratory infection (pooled ARD 0.23, 95 percent CI 0.03; 0.43),^62,^ ^67^ muscle pain (pooled ARD 0.31, 95 percent CI 0.21; 0.41),^62,^ ^67^ malaise and fatigue (ARD 0.45, 95 percent CI 0.32; 0.58),^62^ anorexia (ARD 0.35, 95 percent CI 0.23; 0.47),^62^ nausea and vomiting (ARD 0.21, 95 percent CI 0.07; 0.35),^62^ fever/chills (ARD 0.53, 95 percent CI 0.41; 0.66),^62^ alopecia (ARD 0.30, 95 percent CI 0.173; 0.43),^62^ fever (ARD 0.88, 95 percent CI 0.81; 0.95),^67^ and decreased WBCs (ARD 0.25, 95 percent CI 0.14; 0.35).^67^ Discontinuation of combined therapy due to adverse effects did not differ compared to lamivudine alone across different patient populations.^62,^ ^67,^ ^72,^ ^74,^ ^75,^ ^77,^ ^79^ Chinese patients with HBeAg-negative CHB experienced serious adverse events, including pyrexia, fatigue, myalgia, and headache more often after combined therapy compared to lamivudine alone (ARD 0.09, 95 percent CI 0.02; 0.17).^76^

In conclusion, adverse events requiring dose reduction or discontinuation of medication are relatively common in patients with CHB treated with interferon alfa-2b alone or in combination with other antiviral therapies.

Lamivudine compared to placebo ^67,^ ^130^–^133,^ ^136,^ ^139,^ ^140,^ ^142,^ ^145^ did not require discontinuation of therapy due to adverse effects in HBeAg-positive patients (International Lamivudine Investigator Group),^67^ serious adverse events in Asian patients with advanced cirrhosis or fibrosis (Cirrhosis Asian Lamivudine Multicentre Study Group),^132^ or any adverse events in HBeAg-positive^132,^ ^145^ or HBeAg-negative patients (Lamivudine Precore Mutant Study Group).^142^ Lamivudine prevented worsening of liver necroinflammatory scores in Asian^130,^ ^145^ and American HBeAg-positive patients^136^ but was not effective in HBeAg-negative Asian patients^139^ or in patients who did not respond to previous interferon alfa-2b therapy.^67^ Lamivudine compared to telbivudine resulted in comparable rates of any adverse events in HBeAg-positive patients (Telbivudine Phase II Investigator Group).^127^ In all examined adverse effects, only the rates of dyspepsia (21 versus 0 percent) were higher after lamivudine administration compared to telbivudine.^127^ Combined therapy with telbivudine and lamivudine compared to telbivudine increased the rates of depression (5 versus 0 percent) in HBeAg-positive patients, participants in the Telbivudine Phase II Investigator Group.^127^ One large RCT of 1,370 patients with CHB, participants in the Globe Study Group,^143^ experienced a reduction in HBV DNA reappearance and the rates of treatment-emergent resistance mutations after telbivudine compared to lamivudine therapy.

In conclusion, HBeAg-negative Asian patients and patients tolerant to interferon alfa-2b therapy did not benefit from lamivudine therapy. Telbivudine had comparable safety compared to lamivudine with lower probability of relapse and resistance.

Peginterferon alfa-2a. The HBeAg-Negative Chronic Hepatitis B Study Group^95^ and the Peginterferon alfa-2a HBeAg-Positive Chronic Hepatitis B Study Group^96^ reported increased rates of more than one adverse effect in both patient populations (89 versus 56 percent in HBeAg-positive patients and 86 versus 48 percent in HBeAg-negative patients) and more than one serious adverse effect (7 versus 3 percent in HBeAg-negative patients and 6 versus 2 percent in HBeAg-positive patients) as well as discontinuation of therapy for safety reasons (4 versus 1 percent in HBeAg-positive patients and 4 versus 0 percent in HBeAg-negative patients) after combined peginterferon alfa-2a with lamivudine compared to lamivudine alone.

Adverse event rates varied among patients with different HBeAg baseline status without statistical significance among them (p value for meta regression >0.05). Combined therapy increased the rates of alopecia (11 versus 1 percent in HBeAg-negative and 29 versus 2 percent in HBeAg-positive), arthralgia (15 versus 3 percent in HBeAg-negative and 9 versus 3 percent in HBeAg-positive), dose modification due to adverse events (8 versus 0 percent in HBeAg-positive and 13 versus 0 percent in HBeAg-negative) or laboratory abnormalities (35 versus 0 percent in HBeAg-negative and 38 versus 0 percent in HBeAg-positive).^95,^ ^96^ Fatigue was experienced by 41 percent of HBeAg-negative and 37 percent of HBeAg-positive patients after combined therapy (versus 14 percent and 18 percent after lamivudine alone in HBeAg-negative and positive respectively). ^95,^ ^96^ Myalgia was more common after combined therapy in HBeAg-negative (27 versus 6 percent) and positive (28 versus 3 percent) patients compared to lamivudine alone. More than half the patients experienced pyrexia after combined therapy (54 versus 4 percent in HBeAg-negative and 55 versus 4 percent in HBeAg-positive).^95,^ ^96^

However, several adverse effects were specific for patients with different HBeAg baseline status. Only HBeAg-negative patients experienced dose modification due to neutropenia after combined therapy with lamivudine and peginterferon alfa-2a (24 versus 0 percent after lamivudine alone) or thrombocytopenia (12 versus 0 percent after lamivudine alone).^95^ Combined therapy could not prevent worsening of fibrosis scores from 0 (none) to 18 (severe) in HBeAg-negative patients only (8 versus 3 percent after lamivudine alone).^95^ In contrast, HBeAg-positive patients had depression (6 versus 1 percent), diarrhea (10 versus 3 percent), dizziness (12 versus 4 percent), nausea (10 versus 2 percent), pruritus (10 versus 2 percent), rash (8 versus 4 percent), or rigors (10 versus 0 percent) more common after combined therapy compared to lamivudine alone.^96^ Alopecia (29 versus 20 percent) and YMDD mutations (3 versus 0 percent) were more common in HBeAg-positive patients after combined therapy compared to peginterferon alfa-2a alone.^96^

In conclusion, the moderate level of evidence indicates that a large proportion of patients treated with peginterferon alfa-2a+lamivudine experienced adverse events; the rates varied among patients with different HBeAg baseline status without statistical significance among them.

Monotherapy with peginterferon alfa-2a compared to monotherapy with lamivudine increased the rates of any adverse effects (86 versus 48 percent in HBeAg-negative^95^ and 89 versus 56 percent in HBeAg-positive^96^ patients) and dose modification due to adverse effects (7 versus 0 percent in HBeAg-negative^95^ and 7 versus 0 percent in HBeAg-positive^96^ patients). Pyrexia was more prevalent after peginterferon alfa-2a compared to lamivudine in HBeAg-negative (58 versus 4 percent) and HBeAg-positive (49 versus 4 percent) patients;^95,^ ^96^ however, only patients who were HBeAg-positive at baseline experienced ≥1 serious adverse event (4 versus 2 percent),^96^ while only HBeAg-negative patients needed dose modification due to neutropenia (17 versus 0 percent) or thrombocytopenia (19 versus 0 percent).^95^ As expected, the rates of YMDD mutations were lower after interferon compared to lamivudine (0 versus 25 percent) in patients with HBeAg-positive CHB.^96^

In conclusion, peginterferon alfa-2a resulted in very high rates of adverse events and increased the need to modify treatment dose due to adverse events independent of baseline HBeAg status.

Absolute rates of outcomes by baseline HBeAg status. We summarized the absolute probability of examined outcomes and frequent adverse events (>10 percent) at the end and at followup off the active drugs in trials that included predominantly HBeAg-positive (>98 percent) or HBeAg-negative (>98 percent) patients (Appendix E Table 11). Since none of the treatment regimes demonstrated consistent positive effects on clinical outcomes or all intermediate outcomes, treatment decisions must be made based on a balance between absolute rates of positive intermediate outcomes and harm effects. Some treatments have never been compared to placebo or to each other in head-to-head RCTs. Indirect comparisons were not possible to examine due to differences in comparators in eligible RCTs. However, consumers, clinicians, and policymakers can analyze the balance between treatment effectiveness and harms for clinical and economical decisions.

Adefovir. At the end of adefovir administration, 1 percent of HBeAg-negative patients experienced HBsAg seroconversion, 63 percent had HBV DNA clearance, 36 percent had improved histology, and 66 percent had normal ALT (Appendix E Table 11). The rates of mutation were 4 percent. Sustained HBV DNA loss and improved histology were found in 66 and 71 percent HBeAg-negative patients, respectively. Any adverse events were reported in 70 percent of HBeAg-negative patients treated with adefovir. Abdominal pain, flu-like syndrome, pharyngitis, and asthenia were among the most common adverse events. Virological outcomes in HBeAg-positive patients were assessed at the end of the treatments only (Appendix E Table 11). HBV DNA clearance was demonstrated in 25 percent, HBeAg loss in 17 percent, and HBeAg seroconversion in 12 percent of the patients. Nine percent had virological relapse measured by HBV DNA. Sustained ALT normalization was less common in HBeAg-positive patients (39 percent) compared to HBeAg-negative patients (54 percent). Almost all (95 percent) HBeAg-positive patients experienced some adverse events after adefovir. Asthenia was more common (29 percent) in HBeAg-positive patients compared to HBeAg-negative (10 percent). More than 10 percent of HBeAg-positive patients experienced elevated ALT and urine glucose levels.

In conclusion, more than half of HBeAg-negative patients had sustained HBV DNA clearance, ALT normalization, and histological improvement. HBsAg loss occurred in <10 percent. Overall adverse events were frequent; asthenia and flu like syndrome were observed in approximately 15 percents of HBeAg-negative patients. Sustained outcomes in HBeAg-positive patients have not been examined, yet at the end of the treatment half of the patients had improved histology, <25 percent loss HBV DNA, and HBeAg. Adverse events were very common; asthenia and flu like syndrome were reported more frequent than among HBeAg-negative patients.

Entecavir (Appendix E Table 11). At the end of the therapy HBsAg loss was observed in 4 percent and HBsAg seroconversion in 2 percent of HBeAg-positive patients, sustained HBsAg response in HBeAg-negative patients have not been investigated yet. At the end of the treatments, 15 percent of HBeAg-positive patients experienced HBeAg clearance and 17 percent seroconversion; sustained response was not available from the published trials. HBV DNA clearance at the end of the treatment was more common in HBeAg-negative patients; sustained response was reported in HBeAg-positive patients only and was <10 percent. HBeAg-negative patients had normal ALT and improved histology more often compared to HBeAg-positive patients, More than half the patients reported adverse events, the rates were higher among HBeAg-positive patients; however, elevation of ALT was observed in 10 percent of HBeAg-positive patients.

In conclusion, sustained response to entecavir therapy was reported in HBeAg-positive patients and was small. More than half of HBeAg-negative patients had improved histology and 90 percent loss HBV DNA at the end of the treatment. More than half the patients reported adverse events, but only the rates of elevated ALT in HBeAg-positive patients exceeded 10 percent.

Telbivudine (Appendix E Table 11). Evidence was available only for HBeAg-positive patients at the end of the therapy. HBeAg loss or seroconversion demonstrated 25 percent, ALT normalization 82 percent, and HBV DNA clearance 55 percent; 5 percent had virological relapse with reappeared HBV DNA. Total adverse events were common; however, only the rates of influenza exceeded 10 percent.

In conclusion, there is low to moderate level of evidence that telbivudine has been examined exclusively in HBeAg-positive patients. Sustained response to telbivudine in HBeAg-negative patients is not known. Half of the treated HBeAg-positive patients lost HBV DNA and a quarter had HBeAg clearance. Total adverse events were common (70 percent); however, only the rates of influenza exceeded 10 percent.

Interferon alfa-2b (Appendix E Table 11). Sustained HBsAg loss was uncommon in both HBeAg-positive and negative patients. Sustained HBeAg loss was 43 percent and sustained HBeAg seroconversion was 32 percent among those with HBeAg-positive at baseline. Sustained HBV DNA clearance was 27 percent Sustained ALT normalization and histological improvements have not been examined in HBeAg-negative patients; 27 percent of HBeAg-positive patients had improved histology at followup off the treatment. Virological relapse in HBeAg-positive and mutation in HBeAg-positive and negative patients were uncommon. More than 10 percent of HBeAg-negative patients needed dose reduction or discontinued therapy due to adverse events; however, almost all HBeAg-positive patients had fever or malaise and fatigue and more than 10 percent reported depressions, anorexia, nausea and vomiting, and other adverse events.

In conclusion, sustained HBV DNA clearance in known only in HBeAg-positive patients. One-third of HBeAg-positive patients experienced HBeAg seroconversion and improved histology. Adverse events were common in HBeAg-positive patients and 24 percent of HBeAg-negative patients discontinued therapy because of adverse events.

Peginterferon alfa-2a (Appendix E Table 11). Virological outcomes were examined in HBeAg-positive patients. Fourteen percent had sustained HBV DNA clearance, 32 percent sustained HBeAg seroconversion, and 37 percent sustained HBeAg loss. Sustained ALT normalization was more common among HBeAg-negative (58 percent) than HBeAg-positive (36 percent) patients. HBeAg-positive patients experienced sustained histological improvement (38 percent) compared to HBeAg-negative patients (29 percent). More than 80 percent of all patients experienced adverse events; pyrexia was the most common adverse event (58 percent). Dose modification was required by 37 percent HBeAg-positive and 46 percent HBeAg-negative patients.

In conclusion, one-third of the patients experienced sustained histological improvement after peginterferon alfa-2a therapy, a third of HBeAg-positive patients had sustained HBeAg clearance, and <15 percent of HBeAg-positive had loss of HBV DNA. Viral clearance in HBeAg-negative patients has not been reported. Most patients had adverse events. Around 40 percent required dose modification.

## Consensus Conference Question 4 What Measures are Appropriate to Monitor Therapy and Assess Outcomes?

### EPC Question 4. What is the evidence that changes in surrogate endpoints in response to treatment are reliable predictors of long-term resolution or slowed progression of disease?

Surrogate outcomes of interest.

- ALT and/or AST levels
- HBV viral load
- Change in HBeAg status
- Liver biopsy findings
- Drug resistance

Clinical outcomes of interest.

- Hepatocellular carcinoma (HCC)
- Liver failure
- Cirrhosis
- Liver-related death
- All-cause mortality

Results. We reviewed all studies eligible for question 2 or question 3 to identify RCTs that assessed clinical outcomes in association with monitored changes in viral load or ALT levels. We conducted an additional literature search to identify original epidemiologic observations of more than 50 subjects that examined the association between clinical outcome and changes in biochemical or virological surrogates in patients with active CHB treated with pharmacological agents approved by the FDA with longer than 1 year of followup (Mesh terms “Biological Factors,” “Disease Progression,” “Hepatitis B, Chronic/prevention and control,” OR “Hepatitis B, Chronic/therapy”). From 646 articles retrieved, and one found with a manual search, seven articles were eligible because they reported the association of change in a putative surrogate of interest due to treatment with a clinical outcome of interest.^182^ We assessed results based on established criteria for determining the validity of surrogate measures: (1) The biological marker must be correlated with the clinical endpoint and (2) the marker must fully capture the net effect of the intervention on the clinical-efficacy endpoint. We used the definition of a surrogate endpoint proposed in a Summary of a National Institutes of Health Workshop: Considerations in the Evaluation of Surrogate Endpoints in Clinical Trials: “a laboratory measurement or physical sign used as a substitute for a clinically meaningful endpoint that measures directly how a patient feels, functions, or survives. A clinical investigator uses epidemiologic, therapeutic, pathophysiologic, or other scientific evidence to select a surrogate endpoint that is expected to predict clinical benefit, harm, or lack of benefit or harm. For a biomarker to serve as a surrogate for the effect of an intervention on a clinical endpoint at the population level, more is required than just the ability of the marker measured on an individual to predict that individual's clinical endpoint. The extent to which a biomarker is appropriate for use as a surrogate endpoint in evaluating a new treatment depends on the degree to which the biomarker can reliably predict the clinical benefit of that therapy, as compared to a standard therapy. Such use generally requires extrapolation from data generated for different treatments than the one under investigation. Substituting a surrogate requires that it not only predicts the clinical outcome of interest but also fully captures all the major effects of the new treatment. Surrogate endpoints might also be used to advise patients about modifications of treatment after they have reached a surrogate endpoint but not yet reached the true clinical endpoint.”

Overall summary

- Evidence presented for questions 2 and 3 indicated that no study was designed to assess the effectiveness of treatment on clinical outcomes, a necessary prerequisite for determining the validity of surrogates. Among studies that reported clinical outcomes, treatments did not improve all-cause mortality, liver related death, hepatic carcinoma, or hepatic decompensation.
- In evidence presented for questions 2 and 3, even fewer studies assessed the association of baseline ‘surrogates’ with clinical outcomes.
- We did not find any RCTs that evaluated the association in the change in potential surrogate due to treatment with a clinical outcome.
- We found associations of certain biochemical, virological, and histological measures with clinical outcomes, and advise caution in calling these measures surrogates.
- Out of the seven included studies, the four that met our inclusion criteria were either long-term followup of prior RCTs, with randomization no longer preserved, or cohort studies of once-treated patients, where potential surrogate markers were assessed in relation to long-term clinical outcomes.
- We identified a critical shortage of studies evaluating of the association of surrogates (or change in surrogates) on clinical outcomes. In most studies, the followup was not adequate, both in terms of duration of followup and assessment of outcome, the endpoint events were few, and methods were not inadequate. There were several ‘missed opportunities’ to further assess associations where it appeared that authors could have been able to report relevant data, but this was not done. Clinical outcomes were combined into a single category, such as ‘liver complications’ or ‘decompensation’ making definitions heterogeneous from study to study and not possible to adequately assess.
- Regarding surrogates and endpoints, there was lack of uniformity in measurement, timing of measurement, definitions, and measurement of effect controlling for relevant effect modifiers, such as treatment.
- Regarding treatment, of the four included studies, two studies were in populations that received interferon versus no treatment or placebo. The effect of treatment was adjusted for in the multivariable model reporting the relevant putative surrogate measure and outcome.^174,^ ^175^ One study evaluated a cohort of interferon treated patients^183^ and one compared lamivudine versus combination of lamivudine and interferon.^106^ None of these studies were adequately designed to assess surrogacy.
- Taken together, these data preclude us from drawing firm conclusions regarding the effect of change in surrogate markers and outcomes, and even less so regarding effect modification by treatment. Therefore, we have low confidence in determining whether any of these listed biochemical, histologic, or virologic measures are adequate surrogate markers. As noted previously, patients with of HBV HBsAg are capable of transmitting the hepatitis B virus to uninfected individuals. Therefore, clearance of HBV HBsAg could be considered an appropriate clinical outcome from the perspective of transmissionprevention and public health, in addition to its possibly being a surrogate for later clinical outcomes in a given patient infected with hepatitis B.

Summary of findings. Of the seven included studies that addressed the question, one reported the association of ALT normalization during end of treatment with interferon versus placebo and hepatic decompensation and death among patients with treatment-naive CHB (HBeAg-positive and HBeAg-negative, with and without cirrhosis);^175^ one study reported the effect of change in HBeAg status at the end of treatment on decompensation among treatment naive, HBeAg-positive CHB patients receiving lamivudine with or without peginterferon alpha 2b;^106^ one study reported the association of detectable DNA during treatment on risk of progression of liver disease among treatment-naive patients with HBeAg-positive CHB treated with interferon alpha (a or b not specified) versus untreated;^174^ and one study reported on the effect of worsening histology on progression of liver disease and cirrhosis and hepatocellular carcinoma, respectively, among a cohort of patients with HBeAg-positive CHB treated with interferon alpha-2a or 2b.^183^

In the other three studies, either the surrogate or endpoint reported did not strictly meet the criteria set forth by the question. For example, one study evaluated worsening necroinflammatory activity on rate of fibrosis progression but did not assess the impact of treatment on necroinflammatory activity or fibrosis (furthermore, fibrosis and cirrhosis are arguably potential surrogate and not clinical outcomes).^171^ Two other studies reported outcome by baseline factors, such as lower fibrosis score at baseline^170^ as a predictor of long-term overall and event-free survival, and staging score at baseline^173^ as a predictor of liver-related complications. These studies are discussed briefly in this section as well, to give the reader perspective on published evidence that implies that these measures are accurate surrogates of clinical outcomes (Appendix E Table 12).

Individual surrogates and effect on outcomes.

ALT normalization and outcomes. One study reported the association between ALT normalization due to treatment and decompensation and death.^175^ This study was a long-term followup of 302 patients (71 percent were male, average age was 34±15 years) with CHB that presented to the Liver Clinic in Palermo, Italy, between January 1982 and December 1991. Patients were eligible if they were HBsAg-positive with ALT at least two times ULN in the past 6 months and active hepatitis with or without cirrhosis on liver biopsy. At baseline, 28.5 percent were HBeAg-positive. Of the 302 patients that met the eligibility criteria, 109 received treatment with interferon alpha (presumed to be 2b; dose and duration not reported) and the remaining were untreated. It is unclear how the decision was made to treat or not treat, but the authors reported that the treated and untreated patients were ‘fully comparable for all baseline and clinical features, except ALT levels.’ The mean length of followup was 94±37.6 months. Followup was defined as number of months from liver biopsy to clinical events, death or last contact. Prior to the first followup visit, 9.6 percent of the patients were lost to followup, yet included in the analysis. The primary outcome was survival. Authors also reported adjusted relative risk for death and decompensation. Decompensation was defined as HCC, ascites, jaundice, encephalopathy, and portal hypertensive bleeding (low level of evidence).

Results.

Decompensation. Multivariate analysis showed that older age, cirrhosis at baseline, and abnormal ALT during followup were independent predictors of decompensation, controlling for treatment with interferon. Compared to those without ALT normalization, patients that had normal ALT levels during treatment had a 76 percent relative risk reduction of decompensation [RR 0.24 (0.1; 0.6)] (low level of evidence).

Death. Multivariate analysis showed that older age, cirrhosis at baseline, and abnormal ALT during followup were independent predictors of death, controlling for treatment with interferon. Compared to those without ALT normalization, patients that had normal ALT levels during treatment had a relative risk reduction of 76 percent in their risk of decompensation [RR 0.24 (0.08; 0.7)] (Table 9 and Appendix E Table 13).

Table 9 Characteristics of included studies

Country/ID | Population/ Design | Treatment | Subjects Included | Dose/ Treatment and Followup Duration | Surrogates | Outcomes | Results | Quality | Comments
Italy^175^ | CHB / cohort | Interferon alpha versus untreated | 302 | Dose NR / 24 weeks / 94 months | ALT normalization during/end of treatment | 1 Decompensation (HCC, acites, jaundice, encephalopathy or portal hypertensive bleeding); 2 Death | Decompensation RR 0.24 (0.1;0.6) Death RR 0.24 (0.0; 0.7) | Moderate | Not primary outcome, secondary analysis
Hong Kong^183^ | HBeAg+ CHB / cohort | All treated with Interferon alpha 2a or 2b | 133, reported: 89 | Dose NR / 24 weeks/ 5 years | 1 HBV DNA at end of treatment (≥10^4^ copies/ml); 2 2 point increase in HAI score on liver biopsy | Liver complications (decompensation or HCC) | Unadjusted OR 3.08 (0.44;22.7) Adjusted RR 5.56 (1.12; 27.6) | Moderate | All treated, subgroups reported
Italy^174^ | HBeAg+ CHB / cohort | Interferon alpha 2a versus untreated | 164 | 9 MU TIW / 4–12 months / 6 years | HBV DNA pattern1 (always or frequently >10pg/ml) | Disease progression: fibrosis stage 4, occurrence of decompensation or HCC | Adjusted OR 1.58 (1.12; 2.25) | Moderate | Selection for treatment and treatment course and duration variable
Hong Kong^106^ | HBeAg+ CHB / cohort | Lamivudine plus peginterferon alpha 2b versus lamivudine | 95 | 100–150 po QD for LAM, 1.5mcg/kg/wk for peg-IFN / 52 weeks for LAM, 32 weeks for peg-INF / 52 weeks | Loss of HBeAg end of treatment | Decompensation (elevated serum bilirubin> 50IU/L+ ALT>2 times ULN | For LAM+ peginterferon-IFN: unadjusted OR: 0.6 (0.03;9.01) For LAM: unadjusted OR 0.87 (0.09; 7.6) | Low | Incomplete followup and reporting, few events
Italy^173^ | HBeAg+ CHB / cohort | All treated with interferon alpha 2b | 101 | 6 MU TIW / 24 months/68 months | Staging score at baseline | Liver related complications (histological progression, ascites, jaundice, encephalopathy, gastrointestinal bleeding or HCC) | HR 1.71 (1.17;2.0) | Low | Baseline predictor rather than surrogate
Greece^170^ | HBeAg- CHB / retrospective cohort | Lamivudine versus interferon alpha versus untreated | 201 | LAM 100–150 mg/day for 3.8 years, Interferon NR / 3–6 years | Fibrosis score at baseline, cirrhosis at baseline | Survival and event-free survival (event defined as HCC, decompensation or liver transplantation) | NR | Low | Historical controls, effect measure not reported
Greece^171^ | HBeAg- CHB / cohort | Interferon alpha versus untreated | 147 | 3–5 MU TIW for 6–12 months | 1 Worsening of necroinflammatory activity (>2 point increase in Ishak grading score); 2 Milder fibrosis at baseline | Annual rate of progression of fibrosis | 1 OR 1.05 (1.03;1.08); 2 OR 1.05 (1.00–1.11) | Low | Historical controls, definitions not clear

In conclusion, the low level of evidence of these findings suggests that ALT normalization due to treatment with interferon alpha may be a possible surrogate to assess the composite endpoint of decompensation and death in patients treated with interferon alpha.

Changes in HBV DNA level during/end of treatment and outcomes. There were two studies that reported the effect of changes in HBV DNA during or at end of treatment and outcome.^174,^ ^183^ The patient populations were distinctly different, as discussed below.

The first study^183^ was a longitudinal cohort study from Hong Kong on 133 HBeAg-positive CHB patients treated with interferon alpha-2a (55 percent) or 2b (45 percent) for 24 weeks between 1989 and 1997 (dose not reported) and followed up for at least 5 years after treatment, and had undergone two serial liver biopsies, the first within 6 months prior to treatment, and the second at 24–48 weeks after treatment. HBV DNA was quantified by RT-PCR with a linear range of 10^3^-10^8^ copies/ml. Of the 133 patients, 89 (67 percent) fulfilled the study criteria. Of these, 77 percent were male, median age was 30 years (range 18–53 years), and median followup was 119.4 months (range 60–238 months). The primary endpoint was ‘liver complications’ defined as HBV-related decompensated liver cirrhosis or HCC. Decompensated cirrhosis was defined as at least one of the following: ascites, spontaneous bacterial peritonitis, encephalopathy, and bleeding esophageal varices. Diagnosis of HCC was made histologically or on imaging studies plus alpha fetoprotein (AFP) of >400ng/ml.

Liver complications. The authors reported an association of HBV DNA ≥10^4^ copies/ml at 24 weeks after treatment with liver complications, among the 89 included patients. Of the 68 patients with HBV DNA ≥10^4^ copies/ml at 24 weeks after treatment, 10 (1.7 percent) developed liver complications, compared to 1 (4.8 percent) out of the 21 patients with HBV DNA <10^4^ copies/ml. We calculated the unadjusted OR for this association to be 3.08 (95 percent CI 0.44; 22.7, p=0.3).

The second study^174^ is a long-term followup of a cohort of 164 consecutive patients with antiHBeAg-positive CHB that presented to liver clinics in Torina, Italy, between 1986 and 1993. Of these, 103 patients underwent treatment with interferon alpha-2a (46 patients participated in two clinical trials and the remaining 57 patients received interferon alpha-2a, 9MU three times weekly for 4–12 months. Twenty-one patients received more than one course of treatment with interferon alpha-2a. These patients were compared to 54 untreated patients that had either served as controls in a prior RCT (n=12) or refused treatment/were not candidates for treatment (n=42). Patients were followed for a median of 6 years (range 21 months to 12 years).

Serum HBV DNA was measured using a hybridization assay (sensitivity 10pg/ml). Negative samples underwent PCR amplification. The primary outcome of interest was the cumulative probability of event-free survival. The authors also reported multivariate analysis of factors influencing disease progression. Disease progression was defined as progression of fibrosis to stage 4, occurrence of decompensation (ascites or variceal bleeding), or development of HCC. HBV DNA was dichotomized as pattern 1 (yes/no) defined as always or frequently >10 pg/ml before and during treatment.

Out of the 164 patients, 128 were considered for analysis of factors influencing outcomes, after excluding 36 patients who did not undergo a second liver biopsy or had decompensated liver cirrhosis at baseline. Of these, 57 (42 percent) had cirrhosis at end of treatment.

Disease progression. Controlling for age, prior history of HBeAg positivity, and treatment with interferon, pattern 1 of HBV DNA (always or frequently >10pg/ml) was associated with increased odds of progression (OR 1.58, 1.12; 2.25) (Table 9 and Appendix E Table 13).

In conclusion, the low levels of evidence among HBeAg-positive CHB patients treated with interferon alpha-2a or 2b for 24 weeks, with HBV DNA levels ≥10^4^ copies/ml at end of treatment, may be a candidate to assess surrogacy for a composite endpoint of liver complications. Low levels of evidence among inpatients with CHB who are antiHBeAg-positive, with HBV DNA levels always or frequently higher than 10 pg/ml during treatment with interferon alpha 2a for 16 to 52 weeks, may serve as a potential surrogate for a composite endpoint of disease progression.

Worsening histology and outcomes. One study reported that changes in histology at end of interferon treatment may be associated with liver complications.^183^ A longitudinal cohort study from Hong Kong included 133 HBeAg-positive CHB patients treated with interferon alpha-2a (55 percent) or 2b (45 percent) for 24 weeks between 1989 and 1997 and followed up for at least 5 years after end of treatment with those who had undergone two serial liver biopsies, the first within 6 months prior to treatment and the second at 24–48 weeks after treatment. All liver biopsies were scored by a single pathologist blinded to treatment and outcomes, according to the modified HAI score (0–18) and Ishak fibrosis score. An increase in modified HAI score of two points was considered significant. Of the 133 patients, 89 (67 percent) fulfilled study criteria. Of these, 77 percent were male, median age was 30 years (range 18–53 years) (median followup was 119.4 months; range 60–238 months). The primary endpoint was ‘liver complications’ defined as HBV-related decompensated liver cirrhosis or HCC. Decompensated cirrhosis was defined as at least one of the following: ascites, spontaneous bacterial peritonitis, encephalopathy, and bleeding esophageal varices. Diagnosis of HCC was made histologically or on imaging studies plus AFP of >400ng/ml.

Eight of the 19 patients with a two point increase in HAI score developed liver complications versus three of the 70 patients without a two point increase in HAI score at end of treatment(42 percent versus 4 percent). The authors reported adjusted relative risk of liver complications. It is unclear what the analysis is adjusted for, but after adjustment ‘of other risk factors,’ the relative risk of liver complications in patients with a two point increase in HAI score was 5.56 (95 percent CI 1.12–27.6) (Table 9 and Appendix E Table 13).

In conclusion, low levels of evidence suggested that among patients with CHB and HBeAg-positive, a two point increase in HAI score at the end of treatment with interferon alpha-2a or 2b for 24 weeks may serve as a potential surrogate for liver complications.

Loss of HBeAg at end of treatment and outcomes. One study^106^ reported that seroconversion in HBeAg status due to treatment with lamivudine alone or lamivudine plus peginterferon is associated with lower risk of hepatic decompensation. Ninety-six patients had previously completed an RCT comparing lamivudine plus peginterferon alpha-2b versus lamivudine monotherapy at a single center in Hong Kong. All patients were treatment-naive CHB, HBeAg-positive, with HBV DNA of at least 500,000 copies/ml and serum ALT 1.3–5 times ULN. They received either lamivudine 100 mg orally once daily for 52 weeks (n=48) or lamivudine 100 mg orally once daily for 52 weeks plus peginterferon alpha-2b at a dose of 1.5 mcg/kg/week for 32 weeks (n=48). After completion of treatment, all patients were followed for at least 52 weeks. HBeAg was measured at the end of treatment (52 weeks in both groups) by enzyme-linked immunoSorbent assay (ELISA). Primary measures of interest were probability of sustained virological response, factors associated with sustained virological response among those treated with combination therapy, and HBeAg seroconversion among nonresponders. Decompensation was defined as elevated serum bilirubin >50 IU/L accompanied with biochemical relapse (defined as ALT elevation greater than two times ULN).

Of the 96 patients, 95 were included in the final analyses. One patient who had HBeAg seroconversion prior to commencement of therapy was excluded. The mean ages reported for combination arm and lamivudine treatment were 32±10 and 35±10 years respectively; and 60 percent and 72 percent of the combination arm and lamivudine treated arm, respectively, were male. The post-treatment followup was 117±34 weeks for the combination arm and 124±29 weeks for the lamivudine arm.

Decompensation. Thirty (63 percent) patients in the combination arm (out of 48) had HBeAg seroconversion; of these, one developed decompensated disease, while 18 (37 percent) remained HBeAg-positive at end of treatment, of which one patient developed decompensated disease. We calculated unadjusted odds ratio of decompensation associated with seroconversion of HBeAg among those receiving combination treatment to be 0.6 (95 percent CI 0.03; 9.01) (p-value 0.7).

Thirteen (28 percent) patients in the lamivudine arm (of 47) had HBeAg seroconversion, one patient developed decompensated disease, and 34 remained HBeAg-positive at end of treatment, out of which three patients developed decompensated disease. We calculated unadjusted odds ratio of decompensation associated with seroconversion of HBeAg among those receiving lamivudine treatment to be 0.87 (95 percent CI 0.09; 7.64, p-value 0.9) (Table 9 and Appendix E Table 13).

In conclusion, the low level of evidence among patients with CHB who are HBeAg-positive, seroconversion at 52 weeks of combination therapy with peginterferon interferon alpha-2a + lamivudine is an incomplete surrogate for the composite endpoint of decompensation. The low level of evidence among patients with CHB who are HBeAg-positive, seroconversion at 52 weeks of treatment with lamivudine HBeAg seroconversion may be an incomplete surrogate for composite end point of decompensation.

Summary of evidence.

- There is no evidence to accurately determine whether biochemical, virological, or histological measures can serve as reliable surrogates to assess the effect of CHB treatments on clinical outcomes.
- There is limited information on the association of potential surrogates of ALT normalization, detectable HBV DNA, worsening histology, and change in HBeAg on composite endpoint of decompensation, cirrhosis and HCC, and all-cause mortality among patients with CHB treated with peginterferon-2a plus lamivudine, interferon alpha-2a or 2b or lamivudine.
- ALT normalization may be a candidate to assess as a surrogate for the composite endpoint of decompensation and death in patients treated with interferon alpha (low confidence).
- Among HBeAg-positive CHB patients treated with interferon alpha-2a or 2b for 24 weeks, HBV DNA levels >104 copies/ml at end of treatment may be a candidate to evaluate as an incomplete surrogate for liver complications (low confidence).
- Among antiHBeAg-positive CHB patients treated with interferon alpha-2a for 16 to 52 weeks, HBV DNA levels always or frequently higher than 10 pg/ml may be a potential surrogate for disease progression (low confidence).
- Among HBeAg-positive CHB patients treated with interferon alpha-2a or 2b for 24 weeks, a two point increase in the HAI score at end of treatment may be a potential surrogate for the composite endpoint of liver complications (low confidence).
- Among HBeAg-positive CHB patients treated with a combination of peginterferon interferon alpha-2a plus lamivudine, HBeAg seroconversion may be a candidate for an incomplete surrogate for decompensation (low confidence).
- Among HBeAg-positive CHB patients treated with lamivudine, HBeAg seroconversion may be an incomplete surrogate for decompensation (low confidence).
- There are no data assessing HBsAg seroconversion among treated patients on clinical outcomes.
- There are no data that assess the effect of drug resistance among treated patients on clinical outcomes.
- We did not find any published studies evaluating change in surrogates after treatment with adefovir or telbivudine and effect on clinical outcomes.

Summary of studies evaluating baseline variables as predictors of clinical outcomes and nonclinical endpoints. Three studies that did not meet the definitions of strictor definitions of associations or outcomes are listed in question 4. We describe these to show associations of baseline or other intermediate markers with outcomes.

Effect of baseline variables on clinical outcomes. Two studies evaluated baseline variables as predictors of long-term outcomes.

Baseline fibrosis score as predictor of liver-related complications.^173^ A cohort study of 101 patients with HBeAg-positive CHB suggested that baseline fibrosis score was a predictor of liver related complications in patients treated with interferon. Patients had to have elevated ALT and staging score of 3 or greater, or ATL >200 IU/L if staging score was <3, in the 12 months prior to treatment. Patients received treatment with interferon alpha-2b at a dose of 6 MU intramuscularly three times weekly for 24 months between 1990 and 1997 and were followed for the next 4.5 years. The average age of the group was 46±0 years, 87 percent were male and the average followup was 68 months (range 5–136 months). The primary endpoint was biochemical and virological response. A secondary outcome was liver-related complication-free survival. Authors used the Cox proportional hazards model to estimate the effect of predictor variables of nonresponse to treatment and baseline fibrosis on liver-related complications. Nonresponders were defined as patients showing elevated ALT and/or detectable HBV DNA during treatment. Liver biopsies at baseline were scored using the Ishak scoring for fibrosis (scored 1–6). Liver-related complications included any of the following: histological progression to cirrhosis, ascites, jaundice, hepatic encephalopathy, gastrointestinal bleeding, or HCC.

Results showed that of the 101 patients, 30 (30 percent) had a sustained response to treatment while 71 (70 percent) were nonresponders. In multivariate analysis, controlling for age and treatment failure, staging score at baseline was a predictor of liver related complications (HR 1.71, 95 percent CI 1.17; 2.0).

Baseline fibrosis score and cirrhosis as predictors of overall and event-free survival.^170^ A retrospective cohort study compared 201 patients with HBeAg-negative CHB that received lamivudine therapy between 1997 and 2001 at four liver centers in Greece. Additional eligibility criteria were elevated ALT, detectable HBV DNA, and histological findings of chronic hepatitis. The dose was 100–150 mg orally once daily for the duration of followup (3.8±1.4 years). These patients were compared to two historical controls, one group of 209 patients that had received treatment with interferon alpha (type of interferon, dose and duration not reported) and followed for 6±2.7 years. The second historical control was a group of 195 patients that remained untreated, with followup of 6.1±3.9 years. Patients were followed until a major event, such as development of HCC or liver decompensation, orthotopic liver transplantation, or death. Controlling for age and type of therapy, lower fibrosis scores and absence of cirrhosis at baseline were independent predictors of survival and event-free survival. Estimates are reported with a significant p-value, but the actual estimates are not reported (Table 9 and Appendix E Table 14).

In conclusion, baseline fibrosis score may be a predictor of composite outcome of liver-related complications for patients undergoing treatment with interferon alpha-2b. Baseline fibrosis and absence of cirrhosis may be predictors of survival and event-free survival in patients with HBeAg-negative CHB treated with lamivudine, interferon alpha, or untreated. These findings do not demonstrate that fibrosis or absence of cirrhosis are validated surrogates to evaluate effect of treatments on clinical outcomes.

Effect of baseline and end of treatment variables on nonclinical outcomes. One study evaluated the effect of baseline and end of treatment variables on nonclinical outcome of rate of fibrosis progression.

Effect of histological fibrosis at baseline and worsening necroinflammatory activity during treatment on rate of fibrosis progression.^171^ This was a retrospective study of patients with HBeAg-negative CHB presenting to liver clinics in Greece between 1993 and 2002. Criteria for treatment included patients with at least two serial liver biopsies, increased ALT, detectable HBV DNA, and histology compatible with chronic hepatitis. One hundred twenty patients were treated with interferon alpha (2a or 2b not specified) at a dose of 3–5MU three times weekly for 6–12 months. The treated patients were compared with 27 untreated patients, who either refused treatment or did not meet eligibility criteria for treatment. The average age for interferon alpha treated and untreated patients was 45±11 and 49±15 years respectively. Eighty-one percent of treated patients were male, while 89 percent of untreated patients were male. All patients underwent liver biopsy prior to treatment and at the end of treatment. Liver biopsies were scored by a single pathologist according to Ishak classification for grade (0–18) and stage (0–6). Patients with a decrease in necroinflammatory activity at followup liver biopsy ≥2 points compared to baseline liver biopsy were considered ‘improved.’ Fibrosis stage of ≥4 was considered severe or advanced. The outcome measure was ‘annual rate of fibrosis’ defined as change in fibrosis score between followup and baseline liver biopsy divided by number of years between the two biopsies. Controlling for age and interferon treatment, worsening of necroinflammatory activity (increase of ≥ 2 points on the Ishak grading score) (OR 1.05, 95 percent CI 1.03; 1.08) and milder fibrosis at baseline (OR 1.05, 95 percent CI 1.0; 1.11) were predictors of worse annual rate of fibrosis progression (Table 9 and Appendix E Table 14).