# Introduction

## Overview

Hepatitis B is a highly prevalent disease with 350 million chronic cases worldwide.^1^ Despite immunization efforts, 6,212 incident cases of hepatitis B were diagnosed in the United States in 2004^2^ and 4,713 cases in 2006.^3^ An estimated 2,000 to 4,000 deaths per year are related to CHB liver diseases,^4^ including liver cirrhosis and hepatocellular carcinoma.^5^ The natural history of hepatitis B is variable but generally indolent for many years to decades. Up to two-thirds of adults infected with hepatitis B virus do not experience symptoms, and approximately 5 percent of acutely infected immunocompetent adults develop CHB. Demographic, clinical, and hepatitis B disease factors are believed to be associated with the development of CHB (CHB), poor prognosis among those who develop CHB, and response to therapy. These include the mode and timing of infection, gender, race/ethnicity, geographic location, comorbid conditions, including alcohol use and coinfections with hepatitis C and human immunodeficiency virus (HIV), as well as biochemical, virological, and histological intermediate measures of hepatitis B activity.

Hepatitis B treatments include nucleos(t)ide analogues categorized as L-nucleosides (lamivudine, emtricitabine, telbuvidine, and clevudine), acyclic phosphonates (adefovir and tenofovir), and cyclopentanes (entecavir). Additionally, interferons (standard interferon and peginterferon) are available. Seven antiviral agents have been approved for use in the United States (standard interferon, peginterferon, lamivudine, telbivudine, adefovir, entecavir, and tenofovir) and several others are under investigation. Antiviral drugs are used either as monotherapy or in combination. Two basic therapy approaches exist. A defined self-limited course (e.g., 4–12 months) followed by monitoring off treatment is generally used for interferon-based therapy. Long-term continuous suppressive therapy is used for other direct antiviral agents. The rationale for these different approaches is to maximize long-term loss of HBsAg, HBeAg, and HBV DNA while minimizing treatment related harms, including the development of antiviral resistance. The latter is marked by appearance of circulating hepatitis B virus with reduced sensitivity to the particular antiviral agent. Clinically this is manifested by biochemical increases in previously normalized ALT levels.

The course of CHB is typically silent and associated with few signs or symptoms of disease for many years. Therefore, the major goals of therapy have been long-term prevention of progression, development of cirrhosis, and hepatocellular carcinoma rather than immediate improvement in symptoms. Because development of clinical outcomes often does not occur for years to decades after diagnosis, most studies of therapies have used short-term intermediate biochemical, virological, and histological responses to assess treatment effectiveness. Additionally, investigators and clinicians have described these intermediate laboratory responses as surrogate measures of treatment effectiveness and substituted these measures for clinical outcome effectiveness evaluations. The primary advantage of the use of these intermediate markers is their ability to evaluate drugs more quickly and in smaller trials than would be required for the demonstration of a reduction in the risk of major clinical events.

The Clinical Research Workshop in the Liver Disease Research Branch, National Institute of Diabetes and Digestive and Kidney Diseases,^6^ the American Association for the Study of Liver Diseases,^1^ the Canadian Association for the Study of the Liver, and the Association of Medical Microbiology and Infectious Disease have proposed biochemical, virologic, and histologic measures to determine an individual's risk for disease progression, identify candidates for treatment, and assess treatment effectiveness and harms. There is uncertainty regarding which strategy leads to improved early treatment effectiveness, development of viral resistance while on therapy, sustained off treatment effectiveness (>6 months), harms, costs, and whether treatment outcomes are influenced by patient, disease, or comorbidity factors.

Assessment of these endpoints has been categorized as initial response (measured at 6–12 months on therapy), maintained (longer term on-treatment), and sustained (at least 6 months off treatment). Frequently recommended and utilized intermediate measures have included a decrease in serum ALT levels to normal ranges, resolution of CHB based on HBsAg loss and seroconversion to antiHBsAg, liver biopsy, a decrease in serum HBV DNA to undetected levels, HBeAg loss, or seroconversion to antiHBeAg. All of these proposed endpoints have problems with measurement, standardization, and definitions of normality. For example, not all patients have elevated ALT levels, and there is no widely accepted definition of normal. Liver biopsies are invasive, potentially harmful, difficult to conduct repeatedly, and sample only a small portion of the liver. Complete virological responses are often poorly achieved or relatively short lived. Development of virological resistance and breakthrough requires frequent determinations of HBV DNA levels. Resistance may be genotypic based on detection of HBV mutations that may not be clinically significant. Of greatest importance is the lack of evidence that any intermediate outcomes serve as a true surrogate measure of treatment effectiveness for clinical outcomes. While these measures may be correlated with health outcomes in prospective reports, such a correlation does not prove surrogacy. A surrogate endpoint of a clinical trial is a laboratory measurement or a physical sign used as a substitute for a clinically meaningful endpoint that measures directly how a patient feels, functions, or survives. Changes induced by a therapy on a surrogate endpoint are expected to reflect changes in a clinically meaningful endpoint. For an intermediate outcome to serve as a valid surrogate endpoint, it is required that the effect of the intervention on the surrogate endpoint predicts the effect on the clinical outcome. Valid surrogate endpoints must correlate with the true clinical outcome and fully capture the net effect of treatment on the clinical outcome. Reasons for failure of intermediate measures to serve as surrogates include: the surrogate may not be on the causal pathway of the disease process; of several causal pathways of disease, the intervention affects only the pathway mediated through the surrogate; the surrogate is not in the pathway of the intervention's effect or is insensitive to its effect; or the intervention has mechanisms of action independent of the disease process.

Examples of intermediary measures known to correlate with clinical outcomes and later demonstrated not to be surrogates of treatment include: use of CD4 cell counts to assess whether antiviral therapies improve survival among individuals with human immunodeficiency virus, pharmacologic suppression of ventricular arrhythmias to reduce cardiovascular-related mortality, assessment of improvement in exercise tolerance, and ejection fraction to evaluate impact of pharmacologic interventions on survival in patients with congestive heart failure and bone mineral density improvements due to fluoride to assess fracture risk. While surrogate endpoints can be useful in phase 2 trials for identifying whether a new intervention is biologically active, they are rarely, if ever, adequate substitutes for definitive clinical outcomes in phase 3 trials. We focused our primary assessment of treatment effects on clinical outcomes, including: overall and disease specific mortality and hepatocellular carcinoma. We also included cirrhosis, though many individuals with cirrhosis are asymptomatic and only detected based on study or clinically desired biopsy. Therefore, while cirrhosis is a known poor prognostic indicator, it may be better described as an intermediate, and not a clinical outcome.

Chronic carriers of HBsAg have substantially higher rates of hepatocellular carcinoma, cirrhosis, and death than people who are not HBsAg-positive. Infection with Hepatitis B virus (HBV) can be transferred through multiple different pathways (Figure 1). Combining this individual variation with the demographic diversity within HBV-infected populations makes it difficult to predict individualized outcomes from population-based studies. Furthermore, much of the literature provides incomplete detail to characterize risk factors for progression. This holds true when evaluating observational studies to determine the long-term prognosis of CHB or when assessing outcomes from randomized treatment trials where treatment duration and followup off treatment are often limited in duration (months) yet outcomes due to CHB may require decades to manifest.

Figure 1. Classic phases in chronic Hepatitis B infection (HBeAg-positive)

Previous reviews analyzed efficacy of particular pharmacological agents for chronic HBV infection.^146,^ ^147^ The aim of this report is to systematically analyze evidence of the natural history of CHB as well as treatments for adults to provide evidence for a National Institutes of Health (NIH) Consensus Conference related to Management of Chronic Hepatitis B in Adults. We emphasize treatments most relevant to clinical practice in the United States. We addressed the following NIH Consensus Conference and Agency for Healthcare Research and Quality (AHRQ) Evidence-based Practice Center (EPC) report questions. We developed an analytic framework (Figure 2) that presents these questions in a graphical format along with the key linkages required to assess CHB natural history as well as the effectiveness and harms of treatments.

Figure 2. Hepatitis B analytic framework

### Key Questions

Consensus conference question 1. Which persons with hepatitis B should be treated?

EPC question 1. What is the evidence that the following population characteristics or clinical features associated with hepatitis B are predictive of hepatocellular carcinoma, liver failure, cirrhosis, liver-related death, and all-cause mortality?

Consensus conference question 2. What are the benefits and risks of the current therapeutic options for hepatitis B with defined or continuous courses of treatment?

EPC question 2a. What is the efficacy (or effectiveness) of interferon therapy, oral therapy, and various combinations in treating hepatitis B with defined or continuous courses of treatment?

EPC question 2b. What are the known harms of interferon therapy, oral therapy, and various combinations in treating hepatitis B with defined or continuous courses of treatment?

Surrogate outcomes of interest. Alanine aminotransferase (ALT) and/or aspartate aminotransferase (AST) levels, HBV viral load, change in hepatitis B e antigen (HBeAg) status, HBsAg conversion, liver biopsy findings (necroinflammatory activity or stage of fibrosis), and drug resistance.

Clinical outcomes of interest: hepatocellular carcinoma, liver failure, cirrhosis, liver-related death, all-cause mortality.

Consensus conference question 3. Which persons with hepatitis B should be treated?

EPC question 3a. Are there differences in efficacy/effectiveness of treatments for treatment naïve vs. drug-resistant patients, HBeAg-positive vs. HBeAg-negative patients, or for other subpopulations (as defined previously)?

EPC question 3b. Is there evidence that specific subpopulations do not require treatment for hepatitis B (i.e., that the surrogate and/or clinical outcomes are equivalent or superior when not exposed to treatment?)

Consensus conference question 4. What measures are appropriate to monitor therapy and assess outcomes?

EPC question 4. What is the evidence that changes in surrogate endpoints in response to treatment are reliable predictors of long-term resolution or slowed progression of disease? Patient Population: Adults (≥ 18 years of age), including elderly and members of racial/ethnic minority populations.