# Appendix E Tables and Figures

Figure 1 Flow Chart for Key Questions

Figure 2 Effects of interferon alfa-2b and reverse transcriptase inhibitors on clinical outcomes compared to placebo or no active treatment—Relative risk from four individual RCTs^51,^ ^54,^ ^84,^ ^89^

Figure 3 Comparative effectiveness of interferon alfa-2b and reverse transcriptase inhibitors on mortality, results from individual randomized controlled clinical trials^73^–^76,^ ^90,^ ^101^

Figure 4 Comparative effectiveness of active drugs on clinical outcomes, results from individual RCTs

Figure 5 Effects of active treatments compared to placebo on HBsAg loss at the end of the treatment (results from individual RCTs^47,^ ^84,^ ^89,^ ^96,^ ^98,^ ^103^)

Figure 6 Effects of active treatments compared to placebo on HBsAg loss at followup off the treatment (results from individual RCTs)^46^–^48,^ ^83,^ ^84,^ ^86,^ ^89^

Figure 7 Comparative effectiveness of active treatments on HBsAg loss at the end of the treatments (results from individual RCTs)^43,^ ^47,^ ^64,^ ^73,^ ^78,^ ^94,^ ^96,^ ^97,^ ^101^

Figure 8 Comparative effectiveness of active treatments on HBsAg loss at followup off the treatments (results from individual RCTs)^47,^ ^62,^ ^63,^ ^66,^ ^78,^ ^81,^ ^82,^ ^85,^ ^91,^ ^92,^ ^95,^ ^122^

Figure 9 HBsAg loss combined with other criteria of resolved hepatitis B at followup off the therapy (results from individual RCTs)^84,^ ^87,^ ^93,^ ^105^

Figure 10 HBV DNA loss at the end of the drug therapies for chronic hepatitis B (significant risk differences from individual RCTs and pooled with random effects model)

Figure 11 HBV DNA loss at followup off the drug therapies for chronic hepatitis B (significant risk differences from individual RCTs and pooled with random effects model)

Figure 12 Significant effects on HBeAg loss for chronic hepatitis B (significant risk differences from individual RCTs and pooled with random effects model)

Figure 13 Significant relative risk of virological, histological and biochemical outcomes after drug therapies for chronic hepatitis B (results from individual RCT and pooled consistent results using random effects model)

Figure 14 Significant effects on HBeAg seroconversion for chronic hepatitis B (significant risk differences from individual RCTs and pooled with random effects model)

Figure 15 Significant effects on combined virological and biochemical outcomes at the end of the drug therapies for chronic hepatitis B (significant risk differences from individual RCTs and pooled with random effects model)

Figure 16 Significant effects on combined virological and biochemical outcomes at follow up after drug therapies for chronic hepatitis B (significant risk differences from individual RCTs and pooled with random effects model)

Figure 17 Histological outcomes at the end of the drug therapies for chronic hepatitis B (significant risk differences from individual RCTs and pooled with random effects model)

Figure 18 ALT normalization at the end of the drug therapies for chronic hepatitis B (significant risk differences from individual RCTs and pooled with random effects model)

Figure 19 ALT normalization at followup off the drug therapies for chronic hepatitis B (significant risk differences from individual RCTs and pooled with random effects model)

Figure 20 Combined outcomes at the end of the treatments by baseline ALT levels (individual RCTs)^51,^ ^54,^ ^59,^ ^114^

Figure 21 The effects of lamivudine, 100mg/day compared to placebo at the end of the treatment depending on baseline ALT level (4 lamivudine-controlled Phase III trials)^104^

Figure 22 HBV DNA loss at followup off the drug therapies for chronic hepatitis B by patient pretreatment status, baseline HBeAg positivity, and the proportion of the patients with baseline cirrhosis, the results from individual studies^63,^ ^65,^ ^67,^ ^69,^ ^79,^ ^86,^ ^94,^ ^96^

Figure 23 HBeAg loss and seroconversion at followup off drug therapies for chronic hepatitis B by patient pretreatment status, baseline HBeAg positivity, and the proportion of the patients with baseline cirrhosis, results from individual studies^47,^ ^48,^ ^66,^ ^67,^ ^78,^ ^84,^ ^86,^ ^89,^ ^92,^ ^95,^ ^104,^ ^122^

Figure 24 ALT normalization at followup off drug therapies for chronic hepatitis B by patient pretreatment status, baseline HBeAg positivity, and the proportion of the patients with baseline cirrhosis, results from individual studies^40,^ ^56,^ ^57,^ ^62,^ ^63,^ ^65^–^67,^ ^69,^ ^86,^ ^96,^ ^98,^

Table E1 Evidence table: Observational studies of the natural history of chronic hepatitis B in adults

Author / Country | Design Description | Subject Characteristics | Average Followup / Outcomes Description
A. American Studies
Studies by Livingston/McMahon
Livingston 2007^1^ USA | From a cohort of Alaska Native people with chronic hepatitis B virus (HBV) infection, 47 patients with hepatocellular carcinoma (HCC) and 1129 patients without HCC were genotyped | N=1176. Alaska Native population with HBV genotype F. | 21 years HCC; HBV genotypes
McMahon 2001^2^ | Population based cohort study of HBV carriers observed prospectively for 12.3 years (median) as part of an active surveillance program to detect carriers with HCC | N=1536. Median age of first HBsAg-positive test 20 years (range 1 to 87). Men 59%. | 12.3 years (median) HCC; liver disease mortality; end-stage liver disease
McMahon 2000^3^ | Prospective 16-year, population-based cohort study to determine the impact of screening for HCC in 1,487 hepatitis-B surface antigen (HBsAg)-positive Alaska native carriers with alpha-fetoprotein (AFP) determinations every 6 months. | N=1487. Men and nonpregnant women with an elevated AFP level. Men 59%. | 17 years HCC; mortality
McMahon 1990^4^ | A total of 1400 hepatitis B surface antigen-positive Alaska natives were followed up prospectively over a period of 7815 carrier-years for the development of sequelae related to chronic HBV infection | N=1400 | 5.6 years Cirrhosis; HCC; mortality
Studies by Tong
Tong 2007^5^ USA | 101 hepatitis B surface antigen-positive patients with HCC. Baseline basal core promoter (BCP) T1762/A1764 mutants, precore (PC) A1896 mutants, HBV genotypes and HBV DNA in HCC patients were compared with 67 chronic carriers prospectively. | N=168. [underlined: Chronic carriers (n=67]): Mean age 45.4 ± 12.3 years. Men 29 (43.3%) Asian = 58 (86.6%) AST (mean) = 18.7 ± 11.4 U/L; ALT (mean) = 19.9 ± 13.8 U/L PC: Wild type 70% (n=44); A1896 mutant 30% (n=19). BCP: Wild type 79% (n=37); T1762/A1764 mutant 21% (n=10). [underlined: HCC patients (n=101)] Mean age 53.3 ± 13.5 years. Men 84 (83.2%) Asian = 91 (90.1%) AST (mean) = 128.8 ± 142.6 U/L; ALT (mean) = 92.9 ± 99.4 U/L PC: Wild type 54% (n=54); A1896 mutant 46% (n=46). BCP: Wild type 22.3% (n=21); T1762/A1764 mutant 77.7% (n=73) | 9.3 years HCC
Tong 2006^6^ | A retrospective study in 400 chronic hepatitis B patients in order to identify hepatitis B viral factors associated with complications of liver disease or development of hepatocellular carcinoma. | N=400. Mean age 48.4 years. Men 70.5% [underlined: Serum HBV DNA level:] Baseline (390 patients) = 2.1 log10 – 11.5 log10 copies/mL (median 6.1 ± 2.3 log10 copies/mL). Males (mean) = 6.39 ± 2.30 log10 copies/mL females (mean) = 5.52 ± 2.14 log10 copies/mL [underlined: HBeAg at baseline:] positive = 197 (49.9%) negative = 198 (50.1%) | 7 years HCC; mortality
Tong 2006^7^ | Prospective study The long-term followup of 400 patients who presented to our clinic with chronic hepatitis B is described. | N=400. Mean age 48.4 years. Men 70.5% Asian = 314 (78.5%) patients born in Asia = 70% patients born in North America = 24% | 7 years HCC; mortality
Tong 2001^8^ | 7-year prospective surveillance study to detect hepatocellular carcinoma | N=602. Mean age 51 years. Men 59% | 7 years HCC
Other studies
Schiodt, 2003 ^9^ USA | A retrospective analysis of HBsAg+ patients enrolled in a US Acute Liver Failure (ALF) registry | N=26. Mean age 43 years. Men 54%, Ethnicity: white race 50%. | Survival rate
Thio 2002 ^10^ USA | Multicentre, prospective cohort study classified 5293 men who had sex with men, according to their HIV-1 antibody status, ascertained semiannually, and their HBsAg status, which we ascertained at baseline. | N=326. Homosexual, HIV positive men. | 10.5 years Liver disease mortality
Abiad 2001^11^ USA | Retrospective cohort study was conducted on 231 hepatitis B virus carriers, 65 of whom were also infected with hepatitis D virus, at thirteen Illinois state facilities for the developmentally disabled. | N=231 Men 74.9% Mean age 33 years [underlined: HBV-HDV patients] N= 65 Mean age 37 years Male = 48 (74%) Caucasian = 51 (79%) ALT > 60 U/L = 22 (34%) AST > 42 U/L = 37 (60%) HBeAg positive = 13 (20%) [underlined: HBV only patients] N=166 Mean age 31.4 Male = 125 (75%) Caucasian = 128 (77%) ALT > 60 U/L = 30 (18%) AST > 42 U/L = 52 (31%) HBeAg positive = 41 (25%) | 10 – 12 years Overall mortality, mortality from hepatic disease, and risk of developing chronic hepatitis and cirrhosis
Nomura 1996^12^ USA | Cohort of 5924 Japanese American men was examined for HCC. | N=5924. Men 100%. Ethnicity: Asian race 100%. | 25 years HCC
Norman 1993^13^ USA | Large-scale serological and epidemiological followup study of the epidemic of hepatitis in the US Army in 1942. | N=69,988. White males | 37 years HCC; mortality; liver disease mortality
Weissberg 1984^14^ USA | Survival data from 379 patients with chronic hepatitis B were analyzed to determine life expectancy for the patient from time of first contact | N=379. [underlined: Chronic persistent hepatitis (n=121)] Male (n) = 100 Age (yr) = 35 ± 1 Acute onset (n) = 57 Duration of HBsAg positivity (mo) = 27 ± 2 Alcoholic (n) = 10 Symptoms (n) = 59 ALT (IU) = 75 ± 4 AST (IU) = 66 ± 6 Hep-B DNA polymerase (n) = 85 [underlined: Chronic active hepatitis (n=128)] Male (n) = 112 Age (yr) = 39 ± 1 Acute onset (n) = 72 Duration of HBsAg positivity (mo) = 28 ± 2 Alcoholic (n) = 3 Symptoms (n) = 78 ALT (IU) = 95 ± 5 AST (IU) = 109 ± 9 Hep-B DNA polymerase (n) = 77 [underlined: Chronic active hepatitis w/cirrhosis (n=130)] Male (n) = 121 Age (yr) = 43 ± 1 Acute onset (n) = 67 Duration of HBsAg positivity (mo) = 31 ± 2 Alcoholic (n) = 13 Symptoms (n) = 95 ALT (IU) = 127 ± 6 AST (IU) = 125 ± 13 Hep-B DNA polymerase (n) = 58 | 2.4 years Mortality
Sherman 1995^15^ Canada | Prospective cohort study of chronic carriers of hepatitis B virus, to determine the prevalence and annual incidence of HCC. | N=1069. Mean age 39 years. Men 65%. | 2.2 years HCC; mortality
B. European/Western nations Studies
Amin 2006^16^ Australia | The data from a cohort of 39109 HBV, 75834 HCV and 2604 HBV/HCV coinfected persons notified to the State health department, 1990-2002, were linked to the Cancer Registry and retrospectively analyzed. | N=41,713. Mean age 35 years. Men 55% | 12 years HCC, other cancers
Konopnicki 2005^17^ Europe, Argentina, Israel | A prospective, observational cohort study of 9802 patients with HIV-1 in 72 centers across Europe, including centers in Argentina and Israel. Coinfections with HBV and hepatitis C virus (HBC). | N=5728 (tested for HBsAg) Mean age 36. Men 78% HBsAg negative 5230 (91.3%) HBsAg positive 498 (8.7%) | 7 years Mortality; liver disease mortality
Ribes 2006^18^ Spain | A nested case-control study to determine the role of other risk factors in the mortality from liver disease in HBsAg-positive subjects | N=2352. Mean age 34 years. Men 70%. | 21 years HCC; mortality; liver disease mortality; cirrhosis
Crook 2003^19^ UK | A prospective cohort study of HBsAg-positive blood donors comparing mortality rates in the cohort with the general population. | N=3658. Median age at entry: Men 29 (17 to 64); Women 29 (17 to 65). Men 73%. Subjects born in India/Southeast Asia 8%. | 22 years Mortality; liver disease mortality
B. East Asian Studies
Chan 2008^20^ China | A prospective cohort of patients infected with chronic HBV in a surveillance program for HCC was studied. Ultrasound and alpha-fetoprotein evaluation were regularly performed to detect HCC. Risk factors for HCC and the relationship between HBV DNA and HBV | N=1006. Mean age 48. Men 68%. | 7.7 years HCC
Chen 2007^21^ China | Male cohort of 5,581 hepatitis B surface antigen carriers in Qidong, People's Republic of China, who were recruited starting in 1989. | N=5581. Age range 30 to 65 years. Men 100% | 14 years HCC; mortality
Haimen City Cohort Study
Chen 2006 ^22^ China | A prospective cohort study with 11 year followup which assessed the relationship between past HBV viral load and mortality. | N=2763. Mean age 42 years. Men 61%. History of clinical hepatitis 30%. HBeAg+ at baseline 44%. Family history of HCC 12%. Current alcohol drinker (>4×/week) 38%. Current smoker 39%. | 11 years HCC; mortality
Chen 2005^23^ China | Analyzed all-cause mortality related to HBV infection, focusing on the deaths not related to liver disease in a prospective cohort of adults living in Haimen City, China, who were followed from 1992 to 2002. | N=83,794. Age range 25 to 64 years. Men 70%. Male HBsAg+ 15% (n=8768) Female HBsAg+ 11% (n =2711) | 10 years Mortality
Evans 2003^24^ | 8-year followup of a prospective cohort study in Haimen City, China, identifying HCC risk factors in addition to HBV infection. Two cohorts of adults between ages 25 and 64 years at study entry were followed | N=83,885. Age range 25 to 64 years. Men 70%. 1. Male (n=58454) Age (years) 25–34 19%; 35–44 36%; 45–54 29%; 55–64 17%. 2. Female (n=25340). Age (years) 25–34 24%; 35–44 39%; 45–54 25%; 55–64 12%. | 10 years HCC
London 1995^25^ | Nested case-control study of 183 patients (of 60,984 enrolled) who died from HCC | N=183. Age range 30 to 64 years. | 2.5 years HCC; mortality
REVEAL-HBV Study
Chen 2006^26^ Taiwan | A prospective cohort study with 11 yr of followup; assessed the relationship between past HBV viral load and mortality. Surviving cohort members were evaluated for current liver disease. | N=3653. Age range 30 to 65 years. Men 62%, Age, y (%) 30–39 = 1216 (33) 40–49 = 1014 (28) 50–59 = 1058 (29) ≥60 = 365 (10) Alcohol consumption = 451 (12%) Level of ALT, U/L (%) <45 = 3435 (94) ≥45 = 218 (6) [underlined: Level of HBV DNA, copies/mL] [HBeAg negative] <300 (Undetectable) = 865 (28.0) 300–999 = 372 (12.1) 1000–9999 = 773 (25.0) 10 000–99 999 = 625 (20.2) 100 000–999 999 = 298 (9.7) 1 to 9.9 million = 96 (3.1) 10 to 99.9 million = 42 (1.4) ≥100 million = 17 (0.6) [HBeAg positive] <300 (Undetectable) = 8 (1.4) 300–999 = 0 1000–9999 = 16 (2.8) 10 000–99 999 = 18 (3.2) 100 000–999 999 = 51 (9.0) 1 to 9.9 million = 58 (10.3) 10 to 99.9 million = 58 (10.3) ≥100 million = 356 (63.0) [HBeAg total] <300 (Undetectable) = 873 (23.9) 300–999 = 372 (10.2) 1000–9999 = 789 (21.6) 10 000–99 999 = 643 (17.6) 100 000–999 999 = 349 (9.6) 1 to 9.9 million = 154 (4.2) 10 to 99.9 million = 100 (2.7) ≥100 million = 373 (10.2) | 11 years HCC; mortality
Iloeje 2006^27^ | A population-based prospective cohort study of 3582 untreated HBV patients established in Taiwan from 1991 to 1992. | N=3582. Mean age 45. Men 61%. Alcohol drinkers 12%. | 11 years Mortality; cirrhosis
Studies by Yu
Yu 2005^28^ Taiwan | Baseline blood samples were collected from 4841 Taiwanese men who were HBV carriers but had not been diagnosed with HCC. | N=4841. Men 100%. | 14 years HCC
Yu 1999^29^ Taiwan | A cohort of 4,841 male chronic carriers of HBV surface antigen aged 30 to 65 years who were free of diagnosed HCC was recruited from the Government Employee Central Clinics and the Liver Unit of Chang-Gung Memorial Hospital in Taiwan from 1988 to 1992 | N=4841. Age range 30 to 65 years. Men 100%. | 9 years HCC
Studies by Wang/Yang
Wang 2003^30^ | Prospective community-based cohort study. HBsAg and antibody to HVC in serum were determined | N=11,837. Age range 30 to 64 years. Men 100%. Other data provided | 7.7 years HCC
Yang 2002^31^ | Prospective community-based cohort study of 11,837 without evidence of HCC from seven townships in Taiwan. | N=11,837. Age range 30 to 65 years. Men 100%. Other data provided | 7.8 years HCC
Other studies
Yuen 2005^32^ China | A total of 3233 Chinese chronic HBV patients were monitored for liver biochemistry, viral serology, HBV DNA levels, acute exacerbation, HBeAg seroconversion, and development of cirrhotic complications. | N=3233. Mean age 38 years (range 1 to 85). Men 66%. | 3.9 years HCC; mortality
Jee 2004^33^ Korea | A prospective cohort study of liver cancer in Korea to assess the independent effects and interactions of smoking, alcohol consumption, and hepatitis B on risk of mortality from HCC. | N=605,844. Men 79%. | 9 years Liver disease mortality
Lam 2004^34^ Hong Kong | | N=1863 | Mortality
Tanaka 2004^35^ Japan | A community-based prospective study was conducted for over 8 years by record linkage to the Osaka Cancer Registry. The subjects were 1,927 individuals who were positive for antiHCV through screening for second generation HCV antibody in voluntary blood donors. The risk factors for HCC and interaction between HCV and hepatitis B virus (HBV) infection were evaluated by including additional blood donors: 2,519 individuals positive for hepatitis B virus surface antigen (HBsAg) alone, 25 positive for both antiHCV and HBsAg | N=2544 Mean age 48 years. Men 61%. | 9 years HCC
Mori 2000^36^ Japan | A community-based prospective study examined the effects of viral infections and lifestyle habits on HCC risk in Japan. | N=3052. Mean age 58 years. Men 32%. Age < 54 37%; 55 – 69 43%; ≥ 70 21%. HBsAg-negative 97%. History of habitual alcohol consumption: no 65%; yes 35.0% Presence of chronic hepatitis: no 97%; yes 3% | 5 years HCC
Yu 1999^37^ Taiwan | Male asymptomatic HBsAg carriers were enrolled in the study to investigate prospectively for liver cirrhosis and HCC at 6-month intervals by means of ultrasonography and clinical assessment. | N=1506. Men 100%. | 7.1 years HCC; cirrhosis
Tokudome 1987^38^ Japan | This prospective study investigated whether female Japanese hepatitis B surface antigen positive blood donors were at high risk for HCC. | N=3769. Women 100%. | 8 years HCC; mortality; liver disease mortality
Beasley 1981^39^ Taiwan | Prospective population study of Chinese men (government employees) in Taiwan. | N=22,707. Age range 40–59 years 82%. Men 100%. HBsAg positive subjects 15% | 3.3 years HCC; mortality; liver disease mortality

Table E2 Evidence table: Randomized controlled trials for treatment of hepatitis B

Author / Country | Interventions/Treatment Duration | Key Inclusion / Exclusion Criteria | Subject Characteristics | Assay | Study Quality
A. Adefovir (L-nucleotide analogue)
Versus placebo
Zeng, 2006^40^ | Adefovir 10 mg (n=360) Placebo (n=120 × 12 weeks, then all on adefovir (open-label) × 28 weeks, then Adefovir 10 mg (n=360) Placebo (n=120 × 12 weeks | Inclusion: Patients ≥18 years; detectable hepatitis B surface antigen (HBsAg); detectable hepatitis B e antigen (HBeAg); serum HBV DNA ≥10 log 6 copies/mL; serum ALT level >1 times ULN(ULN), (and >2 × ULN sometime within the previous 6 months). Exclusion: Hepatocellular carcinoma (HCC); clinical signs of liver decompensation; serum creatinine >1.5 mg/dL; ALT >10 × ULN; hepatitis C D, or HIV*; and ADV therapy or any other anti-HBV therapy within the previous 6 months. | Mean age 32 years (range). Men 83%. Race: Asian 100%. | Polymerase chain reactions (PCR) assay (Roche Molecular Systems). Detection limit = 300 copies/mL. | Allocation concealment: adequate Double-blinded Intent-to-treat analyses: yes Study withdrawals adequately described: yes Funding: pharmaceutical
Hadziyannis, 2003^41^ Adefovir 438 Study Group Multinational: Canada, Greece, Israel, France, Italy, Australia, Taiwan, Singapore | Adefovir 10 mg (n=123) Placebo (n=62, 61 included in analyses) × 48 weeks | Inclusion: Patients 16 to 65 years; serum HBsAg present ≥6 months; HBeAg-; DNA ≥10^5^ copies/mL; serum ALT level 1.5 to 15 × ULN; creatinine ≤1.5 mg/dL; adequate blood count. Exclusion: Decompensated cirrhosis; therapy with corticosteroids, immunosuppressive drugs or antiviral agents during last 6 months; hepatitis D, HIV. | Mean age 46 years (range 18–65). Men 83%. Race: white 66%; Asian 30%; black 3%. All subjects were HBeAg-negative. Cirrhosis 11%. Prior HBV treatment: Interferon 41%; Lamivudine 8%; Famiciclovir 8%. | Spot Molecular Hybridization (Genostics, Abbot) | Allocation concealment: unclear Double-blinded Pathologist blinded (biopsy) Intent-to-treat analyses: yes (one dose)* Study withdrawals adequately described: not reported Funding: pharmaceutical
Marcellin, 2003^42^ Adefovir 437 Study Group Multinational: North America, Europe, Australia, Asia | Adefovir 10 mg (n=172, 171 included in analyses) Adefovir 30 mg (n=173) Placebo (n=170, 167 included in analyses) × 48 weeks | Inclusion: HBeAg+; compensated liver disease; PT ≤1 second above normal; albumin ≥3g/dL, bilirubin ≤2.5 mg/dL; creatinine ≤1.5 mg/dL; adequate blood count. Exclusion: Serious comorbidities; immune therapies including steroids; within 6 months; α-fetoprotein ≥50 ng/mL; hepatic mass; prior hepatitis B therapy, hepatitis C or D or HIV. | Mean age 35 years (range 16–68). Men 74%. Race: Asian 59%; white 36%; black 3%; other 2%. All subjects were HBeAg-positive. Prior HBV treatment: Interferon 24%. | Liquid Hybridization (Abbott). Detection limit = 1.6 pg/mL | Allocation concealment: unclear Double-blinded: yes Pathologist blinded Intent-to-treat analyses: yes (one dose) Study withdrawals adequately described: yes Funding: pharmaceutical
Versus lamivudine
Peters, 2004^43^ Australia, Canada, France, Germany, UK, and the US. | Adefovir 10 mg (n=19) Lamivudine 100 mg (n=19) Adefovir and Lamivudine (n=20) × 48 weeks | Inclusion: 16–65 years; serum HBsAg present ≥6 months, positive for HBeAg+; serum ALT level 1.2 to 10 × ULN on at least 2 occasions at least 1 month apart within the preceding 6 months). Exclusion: Serum creatinine level ≥1.5 mg/dL; creatinine clearance ≥50 mL/min; prior use of adefovir or treatment with interferon or other immunomodulatory therapies within the 6 months preceding study screening; treatment with nephrotoxic drugs, competitors of renal excretion, and/or hepatotoxic drugs within 2 months before study screening or during the study period; prior organ transplantation; serious concurrent medical conditions, including other concurrent liver diseases; coinfection with HIV; current alcohol or substance use. | Median age 45 years (range 26 to 69). Men 79%. Race: white 60%; Asian 36%; black 2%. All patients had received treatment with lamivudine for at least 6 months that was ongoing at the time of randomization with confirmed HBV polymerase gene mutation within the YMDD motif. | PCR assay (Roche Molecular Systems). | Allocation concealment: unclear Double-blinded Intent-to-treat analyses: yes (one dose) Study withdrawals adequately described: yes Funding: not reported
Versus telbivudine
Chan, 2007^44^ 018 Study Group Multinational: Hong Kong, Australia, Canada, France, Korea, Taiwan, Singapore, Thailand, and U.S. | Adefovir 10 mg (n=45) Telbivudine 600 mg (n=45) Adefovir 10 mg Telbivudine at week 24 (n=46) × 52 weeks | Inclusion: Patients with treatment naïve HBV; HBeAg+. Exclusion: ALT <1.3 × ULN; ALT >10 × ULN; HBV DNA <6 log10 copies/mL; HBsAg negative; low absolute neutrophil count; α-fetoprotein <50 ng/mL; amylase >1.5 × ULN | Mean age 32 years (range 18–60). Men 76%. Race: Asian 92%; white 4%; other 4% All subjects were HBeAg-positive and treatment naïve | PCR assay (Roche Molecular Systems). Detection limit = 300 copies/mL | Allocation concealment: adequate Open-label Intent-to-treat analyses: no Study withdrawals adequately described: yes Funding: pharmaceutical
Versus combined lamivudine and adefovir
Akyildz, 2007^45^ | Adefovir 10 mg (n=25) Adefovir 10 mg and lamivudine 100 mg combination during first 3 months, and then adefovir monotherapy (n=29) × 52 weeks | Inclusion: HBsAg present given lamivudine therapy ≥6 months; HBV polymerase gene mutation in the YMDD motif; DNA level >5 log10 copies/mL; ALT 1.2 × ULN; compensated liver disease and no history of variceal bleeding, ascites, or hepatic encephalopathy. Serum albumin levels >3 g/dl; total bilirubin levels <2 mg/dl; Child-Pugh-Turcotte score <7. Exclusion: Serum creatinine level >1.4 mg/dl or creatinine clearance <50 ml/minute; HIV or hepatitis C; serum α-fetoprotein >50 ng/ml, previous AD therapy, receiving nephrotoxic or hepatotoxic drugs; coexisting other chronic liver diseases (metabolic liver diseases and alcoholic liver disease); organ transplantation; malignancy. | Median age 48 years (range). Men 63%. 65% were HBeAg-negative. All subjects were lamivudine resistant. | Real-time PCR (Applied Biosystems) Detection limit = 2000 copies/mL | Allocation concealment: unclear Open-label Intent-to-treat analyses: unclear Study withdrawals adequately described: not reported Funding: not reported
Peters 2004^43^ | See above under adefovir versus lamivudine
* Subjects need to receive one dose to be included in the analyses
B. Lamivudine monotherapy ([underlined: L-nucleoside analog])
Versus placebo
Chan 2007^46^ Anti Viral Therapy Multicenter: China | Lamivudine 100 mg (n=89) Placebo (n=47) × 104 weeks, plus 26 weeks followup | Inclusion: ≥18 years, HBsAg ≥6 months; HBeAg- ≥6 months prior to screening; HBV DNA detectable by non-PCR assay; significantly increased ALT levels (1.3 to 10 × ULN) and liver biopsy within 12 months showing active HBV. Exclusion: HCC; ALT >10 × ULN; hepatitis C or D or HIV; decompensated liver disease; treatment with antiviral or immunomodulatory drugs ≤6 months prior to study; serum creatinine level ≥1.5 ULN. | Mean age 39 years (range 17 to 63). Men 84%. All subjects were treatment-naïve and HBeAg-negative. | Real-time PCR (TaqMan) | Allocation concealment: unclear Double-blinded Pathologist blinded Intent-to-treat analyses: yes Study withdrawals adequately described: no Funding: pharmaceutical
Schiff, 2003^47^ Europe, North America | Lamivudine 100 mg × 52 weeks (n=119) Lamivudine 100 mg × 8 weeks plus Interferon-α-2b 10 MU subcutaneously × 3/week × 16 weeks (n=63) Placebo (n=56) 16 weeks followup | Inclusion: ≥16 years, HBsAg 6 months, HBeAg, hybridization-assay-detectable HBV DNA, ALT ≥ 1.3 × ULN; histologic chronic hepatitis, and previous treatment with ≥240 million units (MU) of IFN; IFN must have been completed ≥6 months earlier, and patients must have failed IFN for lack of efficacy, not intolerance. Exclusion: Prior antiviral treatment for hepatitis B; treatment with antiviral agents, immunomodulatory drugs, or corticosteroids within 6 months prior to study; history of ascites, variceal hemorrhage, or hepatic encephalopathy; coinfection with hepatitis C or D, or HIV; the presence of confounding medical illness or other types of liver disease. | Mean age 37 years (range 15 to 76). Men 81%. Race: white 82%; Asian 7%; other 11%. All subjects were HBeAg-positive and failed interferon therapy previously. | Hybridization assay | Allocation concealment: yes Double-blinded Until week 8 (IFN assigned) Pathologist blinded Intent-to-treat analyses: yes Study withdrawals adequately described: yes Funding: pharmaceutical/government/other
Dienstag, 1999^48^ United States | Lamivudine 100 mg (n=66) Placebo (n=71) × 52 weeks, plus 16 weeks followup | Inclusion: Patients ≥18 years; detectable HBsAg ≥6 months; serum HBeAg ≥1 month; serum ALT 1.3 to 10 × ULN ≥3 months. Exclusion: Prior antiviral treatment for HBV; treatment with antiviral agents or immunomodulatory drugs, history of ascites, variceal hemorrhage, or hepatic encephalopathy; hepatitis C, D, or HIV; presence of confounding medical illness or other types of liver disease. | Median age 38–40 years (range 18–73). Men 83%. Race: white 57%; Asian 20%; black 17%; other 6%. All subjects were treatment-naïve. | Liquid Hybridization (Abbott). Detection limit = 1.6 pg/mL | Allocation concealment: unclear Double-blinded Pathologist blinded Intent-to-treat analyses: yes Study withdrawals adequately described: yes Funding: pharmaceutical/Government
Tassopoulos, 1999^49^ Multinational | Lamivudine 100 mg (n=60) × 52 weeks Placebo (n=64) × 24 weeks | Inclusion: 16 to 70 years of age; detectable hepatitis B surface antigen (HBsAg), detectable HBeAb, and undetectable HBeAg in serum ≥6 months before screening; serum HBV DNA ≥2.5 pg/mL; HBV DNA in the serum ≥3 months; and serum ALT ≥1.5 to 10 × ULN. Exclusion: Decompensated liver disease; hepatitis C or D, or HIV; evidence of autoimmune hepatitis; received an investigational drug within 30 days of the first dose of study drug; received any systemic antiviral therapy or immunomodulators, cytotoxic agents, or corticosteroids within 6 months of screening. | Median age 43 years (range 17–65). Men 80%. All subjects were HBeAg-negative/HBV virus DNA-positive (precore mutant). | Qualitative microparticle enzyme immunoassay (Abbott) | Allocation concealment: adequate Double-blinded Pathologist blinded Intent-to-treat analyses: yes Study withdrawals adequately described: yes Funding: pharmaceutical
Lai, 1998^50^ Multinational: Taiwan, Hong Kong, Singapore | Lamivudine 100 mg (n=143) Lamivudine 25 mg (n=142) Placebo (n=72) × 52 weeks | Inclusion: Patients 16 to 70 years; detectable HBsAg, serum HBV DNA levels of at least 5 pg per milliliter; and ALT <10 × ULN at screening and for at least the previous 3 months. Exclusion: Hepatitis C or D or HIV infection; decompensated liver disease; evidence of autoimmune hepatitis. | Median age 32 years (range 15–67). Men 73%. Race: Asian 100%. All subjects were HBeAg-positive. | In situ hybridization technique | Allocation concealment: unclear Double-blinded Intent-to-treat analyses: yes Study withdrawals adequately described: no Funding: pharmaceutical
Versus placebo, subjects with advanced liver disease
Liaw, 2004^51^ Cirrhosis Asian Lamivudine Multicenter Study Group Multinational: Asian-Pacific region | Lamivudine 100 mg (n=436) Placebo (n=215) Median followup 32.4 months (range 0 to 42). Treatment was stopped for patients who received a clinically confirmed end point. | Inclusion: ≥16 years; positive for HBsAg ≥6 months; positive for HBeAg or negative for HBeAg with detectable HBV DNA at screening, and had had a liver biopsy showing an Ishak fibrosis score of at least 4 (where 0 indicates no fibrosis and 6 indicates cirrhosis) at screening or during the previous 2 years. Exclusion: HCC; serum ALT level >10 × ULN; hepatic decompensation; autoimmune hepatitis; hepatitis C or D or HIV; serious concurrent illness; pancreatic amylase or lipase levels > 2 × ULN; elevated serum creatinine level; treatment with immunomodulatory or antiviral therapy ≤6 months before screening; treatment with any investigational drug within 30 days prior to study; previous treatment with lamivudine. | Median age 43–44 years (range 17–74). Men 85%. Race: Asian 98%. All subjects were HBeAg-positive or were HBeAg-negative with detectable HBV DNA at screening, and had a liver biopsy with an Ishak fibrosis score of 4 (scale 0 to 6, 0 no fibrosis) at screening or in previous 2 years. | Branched-chain hybridization assay (Bayer) Detection limit = 0.7 mEq per m/L. | Allocation concealment: unclear Double-blinded Intent-to-treat analyses: yes Study withdrawals adequately described: no Funding: pharmaceutical
Miscellaneous Lamivudine trials
Jang, 2006^52^ South Korea | Lamivudine 100 mg daily from the start of transarterial chemo-lipiodolization (TACL) (preemptive group, n=38) No lamivudine control group (n=38) | Inclusion: Diagnosis of HCC based on histological evidence or elevated serum a-fetoprotein (AFP) levels (>400 ng/mL) with typical radiological findings. Exclusion: Previous history of antiviral therapy; baseline ALT level ≥2.5 × ULN; serum HBV DNA level >107 copies/mL; extrahepatic metastasis; main portal vein thrombosis; underlying cardiac or renal diseases; positive tests for antibody to hepatitis C virus or HIV; Child-Pugh classification B or C; or preexisting evidence of hepatic decompensation. | Mean age 53 years. Men 84%. HCC patients undergoing using epirubicin 50 mg/m2 and cisplatin 60 mg/m2 at monthly intervals. All patients had HBV genotype C | Branched DNA assay (Bayer) Detection limit = × 10^3^ to 1 × 10^8^ copies/mL). | Allocation concealment: adequate Open-label Intent-to-treat analyses: no Study withdrawals adequately described: yes Funding: Government
Ke, 2005^53^ China | Lamivudine 100 mg (n=42) Routine medication with vitamin C and inosine (n=30) x 48 weeks. | Inclusion: >16 years of age, normal or abnormal ALT, positive HbsAg and HBeAg in serum, negative anti-HCV, anti-HDV and anti-HEV in serum, positive HBV DNA in serum and PBMCs. Exclusion: Other possible causes of chronic liver damages, such as drugs, alcohol and autoimmune diseases. | Mean age 32 years (18–60). Men 69%. | Not reported | Allocation concealment: unclear Open-label Intent-to-treat analyses: yes Study withdrawals adequately described: none reported Funding: not reported
Kim, 2006^54^ South Korea | Patients were assigned either to ongoing lamivudine (n=37) or had lamivudine-therapy-discontinued group (n=37). There was no interruption in lamivudine-therapy before randomization. Median followup was 20 months | Inclusion: HBsAg positive ≥6 months; ≥18 years of age; received lamivudine treatment ≥6 at the time of randomization, who had serum HBV DNA >10^5^ copies/ml and a HBV polymerase gene mutation within the YMDD motif, and who had relatively well-preserved liver function without a history of variceal bleeding, ascites, or encephalopathy. Exclusion: Coexisting serious medical or psychiatric illness; recent treatment with systemic corticosteroids; hepatic mass; seropositivity for HIV or hepatitis C or D; previously received treatment with adefovir or other antiviral agents with activity against HBV. | Mean age 45 years. Men 87%. All patients were ethnic Koreans. All subjects were lamivudine-resistant. | Serum HBV DNA >10^5^ copies/ml (Roche) Detection limit = 200 copies/ml or Digene hybrid capture assay (Digene) | Allocation concealment: adequate Intent-to-treat analyses: yes Study withdrawals adequately described: yes Funding: Institution
Nevens, 1997^55^ | Lamivudine 25 mg (n=16) Lamivudine 100 mg (n=16) Lamivudine 300 mg (n=19) × 24 weeks plus 24 weeks followup | Inclusion: Serum HBV DNA positive, ALT <300 IU/L; serum positive HBsAg and HBeAg for 6 months preceding study Exclusion: Decompensated liver disease; abnormal renal function; hemoglobin concentration, 10 g/dL, white cell count <3 × 10^9^/L, or platelet count <50 × 10^9^/L; coinfection hepatitis C, D, or HIV; previous treatment with antiviral, or corticosteroid therapy | Mean age 36 years. Men 71%. Race: Asian 49%; white 43%, Cirrhosis 20%. Prior HBV treatment: Interferon 37% | Liquid Hybridization (Abbott). | Allocation concealment: Partially double-blinded Intent-to-treat analyses: yes Study withdrawals adequately described: yes
Versus entecavir (see below)
Versus telbivudine (see below)
Versus pegylated interferon-α-2a monotherapy
Lau, 2005^56^ Multinational: Europe, Asia, Australasia, North and South America | Lamivudine 100 mg (n=272) Peginterferon α-2a 180 μg/ week plus placebo (n=271) Lamivudine 100 mg plus Peginterferon α-2a 180 μg/ week (n=271) × 48 weeks, plus 24 weeks followup. | Inclusion: HBsAg ≥6 months, were negative for antibodies to HbsAg (anti-HBs antibodies) and positive for HbeAg, had an HBV DNA level of > 500,000 copies per milliliter, serum ALT level that was >1 but ≤10 × ULN; findings on a liver biopsy within the previous 12 months that were consistent with the presence of chronic hepatitis B. Exclusion: Decompensated liver disease; coexisting serious medical or psychiatric illness; serum creatinine level >1.5 × ULN; history of alcohol or drug abuse within 1 year before entry; hepatitis C or D or HIV. | Mean age 32 years (range 17 to 77). Men 78%. Race: Asian 87%; white 10%; black 1%; other 2%. All subjects were HbeAg-positive. Prior HBV treatment: Interferon 11.5%; lamivudine 12%. Bridging fibrosis or cirrhosis 17%. | PCR-DNA Cobas Amplicor (Roche) and AxSYM test (Abbott) | Allocation concealment: unclear Partially double-blinded Pathologist blinded Intent-to-treat analyses: yes (one dose) Study withdrawals adequately described: yes Funding: pharmaceutical
Marcellin, 2004^57^ Multinational: Europe, Asia | Lamivudine 100 mg (n=181) Peginterferon α -2a (180 μg/ week) plus placebo (n=177) Lamivudine 100 mg plus Peginterferon α -2a 180 μg/ week (n=179) × 48 weeks, plus 24 weeks followup. | Inclusion: Negative for HbeAg and positive for anti-Hbe antibody and HbsAg ≥6 months; HBV DNA level of >100,000 copies/mL; serum ALT level >1 to ≤10 × ULN; findings on a liver biopsy within prior 2 years consistent with the presence of chronic hepatitis B, with evidence of prominent necroinflammatory activity. Exclusion: Decompensated liver disease; coexisting serious medical or psychiatric illness; serum creatinine level that was >1.5 × ULN; history of alcohol or drug abuse within 1 year before entry; treatment for chronic hepatitis B within the previous 6 months; hepatitis C, D virus or HIV. | Mean age 40 years (range 18 to 71). Men 85%. Race: Asian 61%; white 37%; black 1%. All subjects were HbeAg-negative. | PCR-DNA Cobas Amplicor (Roche) | Allocation concealment: unclear Partially double-blinded Pathologist blinded Intent-to-treat analyses: yes (one dose) Study withdrawals adequately described: yes Funding: pharmaceutical
C. Lamivudine versus combination therapy
Versus combined lamivudine and adefovir (see above)
Perrillo, 2004^58^ | Lamivudine 100 mg (n=49) Lamivudine 100 mg plus adefovir 10 mg (n=46) × 52 weeks. | Inclusion: Compensated chronic hepatitis and be HbeAg+ at screening (patients in group B were allowed into the study if they were either HbeAg+ or - as well as elevated serum ALT levels >1.3 × ULN on at least 2 occasions in the previous 6 months): confirmed to have YMDD mutant HBV Exclusion: Hepatitis C or D or HIV; documented or suspected HCC; anemia; screening calculated creatinine clearance <50 mL/min or a serum creatinine value >1.5 mg/dL; pancreatitis; previously treatment with adefovir or other drugs with activity against HBV within the prior 3 months were not eligible. | Median age 43 years (range 24 to 68). Men 96%. | PCR assay (Roche) | Allocation concealment: unclear Double-blinded Intent-to-treat analyses: yes (one dose) Study withdrawals adequately described: yes Funding: not reported
Versus combined Pegylated Interferon α-2a
Lau, 2005^56^ | See under lamivudine monotherapy
Marcellin, 2004^57^ | See under lamivudine monotherapy
Versus combined Pegylated Interferon-α-2b and Lamivudine
Chan, 2005^59^ Multicenter study: China | Lamivudine 100 mg plus pegylated interferon-α-2b 1.5 microg/kg of body weight (patients <65 kg) or 100 mg per week for 32 weeks (n=50) Lamivudine 100 mg (n=50) × 52 weeks. | Inclusion: Age 18 to 65 years; HbsAg positive ≥6 months; serum HBV DNA level of at least 500,000 copies/mL; ALT level 1.3 to 5 × ULN. Exclusion: Decompensated liver disease or a history of interferon or antiviral agent use; hepatitis C or D, or HIV; HCC; other causes of liver disease, including autoimmune hepatitis; Wilson disease; hemochromatosis and a1-antitrypsin deficiency; serious medical or psychiatric illness; concurrent use of corticosteroid or immunosuppressive agents. | Mean age 33 years (range 16–68). Men 67%. All subjects were HbeAg-positive and treatment naïve. | Real-time PCR (TaqMan) | Allocation concealment: adequate Open-label Pathologist blinded Intent-to-treat analyses: yes (one dose) Study withdrawals adequately described: yes Funding: pharmaceutical
Versus combined Interferon-α-2b and lamivudine
Akyuz 2007^60^ Turkey | Lamivudine 100 mg for 24 months plus interferon-α-2b 10 MU/week for 6 months (n=21) Lamivudine 100 mg (n=24) × 24 months. | Inclusion: HbsAg-positive and HbeAg-negative ≥18 months; serum HBV DNA ≥6 months; ALT level 1.3 to 5 × ULN ≥3 months; biopsy proven HBV and compensated liver disease. Exclusion: hepatitis C or D, or HIV | Mean age 43 years (range 20–65). Men 71%. All subjects were HbeAg-negative and interferon resistant. | Molecular hybridization (Digene) and PCR | Allocation concealment: unclear Open-label Intent-to-treat analyses: yes Study withdrawals adequately described: yes Funding: not reported
Lu, 2007^61^ China | Lamivudine × 8 months then interferon-α-2b from months 7 to 12 (n = 24) or interferon-α-2b 5 MU 3 times per week (n = 12). Lamivudine 100 mg (n=35) × 48 weeks, plus 24 weeks followup. | Inclusion: HbeAg-+ chronic hepatitis B Exclusion: Alcoholism; cirrhosis, chronic renal failure; concurrent autoimmune disease, serious neurological disorders, HIV infection or hepatitis A, C, D, or E; treatment with interferon or other anti-viral therapies for 6 months prior to enrollment in this study. | 71 patients, mean age 32 ± 9 (range 19–47) years. 83% male. | PCR-RFLP. | Allocation concealment: unclear Blinding not reported Intent-to-treat analyses: yes Study withdrawals adequately described: no withdrawals reported Funding: not reported
Shi, 2006^62^ China | Lamivudine 100 mg × 20 weeks, followed by interferon-α-2b 5 MU 3 times/ week plus lamivudine × 4 weeks, then interferon-α-2b × 24 weeks (n=64). Lamivudine 100 mg × 48 weeks (n=98). 24 weeks followup | Inclusion: >16 years of age; positive for HbsAg ≥6 months; negative for HbeAg and positive for hepatitis B e antibody (anti-Hbe), and had HBV DNA levels of >100,000 copies/mL and serum ALT levels >1.5 to <10 × ULN. Exclusion: Hepatitis A, C, D, and E virus or HIV: decompensated liver diseases or HCC; history of alcohol or drug abuse within 1 year before entry; other possible causes of chronic liver damage; previous treatment of chronic hepatitis B. | Mean age 34 years (range 20 to 57). Men 72%. Race: Asian 100%. All subjects were HbeAg-negative. | Real-time PCR (Fosun) | Allocation concealment: unclear Open-label Intent-to-treat analyses: yes Study withdrawals adequately described: yes (none) Funding: foundations
Economou, 2005^63^ Multicenter study Greece | Lamivudine 100 mg × 48 weeks plus interferon-α-2b 5 MU 3 times/week (n=24). Lamivudine 100 mg (n=26) × 104 weeks, plus 26 weeks followup. | Inclusion: HbsAg positive, anti-Hbe positive and HbeAg negative serology ≥6 months before enrollment; serum HBV DNA concentrations >105 copies/mL; elevated ALT × 1.5 times the upper normal limit in three separate monthly occasions ≤6 months before randomization; liver biopsy with evidence of chronic hepatitis within 12 months before entering the study. Exclusion: Antibodies against hepatitis C or D or HIV; decompensated liver disease or received liver transplantation; treatment with any antiviral drug other than IFN and those who had received immunosuppressive therapy within 6 months before participation; alcohol consumption >50 g/d or suspected HCC and elevated α-fetoprotein. | Median age 56 years (range 41 to 66). Men 66%. Prior HBV treatment: Interferon: 56%. Cirrhosis 48%. Median values: ALT 79; AST 59 Median values: ALT 59; AST 60 | Microparticle enzyme immunoassay | Allocation concealment: adequate (Lottery cards) Open-label Intent-to-treat analyses: yes Study withdrawals adequately described: yes Funding: not reported
Akarca, 2004^64^ Turkey | Lamivudine 100 mg × 96 weeks plus interferon-α-2b 5 MU 3 times/week × 24 weeks (n=40). Lamivudine 100 mg × 96 weeks (n=40). | Inclusion: HbsAg positive, anti-Hbe positive and HbeAg negative serology ≥6 months before enrollment.; elevated ALT × 1.5 times the upper normal limit on two occasions one month apart. Exclusion: other causes of liver disease (hepatitis C or D or HIV); decompensated liver disease | Mean age 42 years (range 19 to 67). Men 86%. | Hybridization assay (Digene) | Allocation concealment: adequate Open-label Intent-to-treat analyses: unclear Study withdrawals adequately described: no withdrawals reported Funding: not reported
Jang, 2004^65^ South Korea | Lamivudine 100 mg plus interferon-α-2b 5 MU 3 times/week (n=41) Median duration 7 months Lamivudine 100 mg (n=42) Median duration 38 months | Inclusion: Positive for hepatitis B surface antigen (HbsAg), HbeAg, and HBV-DNA ≥ 6 months before the therapy; serum ALT levels >2 times upper limit of normal. Exclusion: Antibody for hepatitis C or D or HIV; liver cirrhosis by histological or clinical examination. | Mean age 37 years. Men 82%. | Solution hybridization assay | Allocation concealment: unclear Open-label Pathologist blinded Intent-to-treat analyses: yes Study withdrawals adequately described: yes Funding: not reported
Schiff, 2003^47^ | See under lamivudine
Barbaro, 2001^66^ Italy Multicenter | Interferon-α-2b 9 MU 3 times/ week plus Lamivudine 100 mg × 24 weeks (n=76) Lamivudine 100 mg × 52 weeks (n=75) 48 weeks followup. | Inclusion: Detectable hepatitis B surface antigen (HbsAg) and HbeAg in serum at the time of screening and for at least the previous 6 months, with serum HBV DNA levels ≥5 pg/ml and with ALT levels that were 1.3 to 10 times ULNfor at least the previous 3 months were eligible for the study. Exclusion: <18 years old; hepatitis C or D or HIV infection; decompensated liver disease; evidence of autoimmune hepatitis or metabolic liver disease; received an investigational drug within 30 days before enrollment or any systemic antiviral therapy, immunomodulators, cytotoxic agents, or corticosteroids within 6 months before enrollment; poor clinical condition and/or had serious medical diseases. | Mean age 41 years (range 32 to 50). Men 83%. Cirrhosis 5%. | Solution hybridization assay (Abbott) | Allocation concealment: adequate Open-label Pathologist blinded Intent-to-treat analyses: yes Study withdrawals adequately described: yes Funding: none from pharmaceutical
Schalm, 2000^67^ Multinational: Europe, Canada, Australia | Lamivudine 100 mg once daily followed by 16 weeks of lamivudine 100 mg plus interferon- α-2b 10 MU 3 times/week (n=75) Interferon-α-2b (n=69) Lamivudine 100 mg × 52 weeks (n=82) Treatment ranged from 24 to 52 weeks, depending on arm. | Inclusion: Ages 16–70 years; detectable HbsAg and HbeAg in serum at the time of screening and for at least 6 and 3 months, respectively, before study entry; serum HBV DNA levels of at least 5 pg/ml at screening; and evidence of inflammation by histology or by raised ALT levels (1.3 × 10 ULN) at screening and ≥3 months before screening with no value falling within the normal reference range in the intervening period. Exclusion: Previous interferon or antiviral treatment within 6 months; were co-infected with hepatitis C or D, or HIV; decompensated liver disease; evidence of liver disease of other etiology. | Median age 31 years (range 15–70). Men 74%. Race: white 63%; Asian 29%. All subjects were HbeAg-positive and treatment naïve. Cirrhosis 16%. | Solution-hybridization- assay (Abbott) | Allocation concealment: adequate Blinded up to week 8 Pathologist blinded Intent-to-treat analyses: yes Study withdrawals adequately described: yes Funding: pharmaceutical
Versus combined Interferon-α (type of alpha unclear) and lamivudine
Scotto, 2006^68^ Italy | Arm A Interferon-α 6 MU 3 times/week lamivudine 100 mg × 52 weeks (n=20) Arm B Interferon-α 6 MU 3 times/week lamivudine 100 mg × 40 weeks after pre-treatment with lamivudine × 12 weeks (n=18) Arm C Lamivudine 100 mg × 52 weeks (n=21) | Inclusion: Serum ALT >2 × normal level for >6 months; HBV infection based on the presence of HbsAg+; HBV DNA+ >5 pg/mL; positive histology for CHB/cirrhosis within 6 months of the study according to the Knodell-Ishak. Exclusion: Hepatitis C, D, or HIV; alcohol abuse; Wilson's disease; hemochromatosis; α-antitrypsin deficiency. | Mean age 44 years (range 23 to 63). Men 54%. All subjects were HbeAg-positive. Cirrhosis 12%. | Sandwich hybridization (Qunatiplex Chiron) | Allocation concealment: unclear Open-label Pathologist blinded Intent-to-treat analyses: yes Study withdrawals adequately described: yes Funding: not reported
Sarin, 2005^69^ India | Interferon-α 5 MU 3 times/week × 16 weeks plus Lamivudine 100 mg × 52 weeks (n=38) Lamivudine 100 mg once daily × 52 weeks (n=37) | Inclusion: Ages 16–70 years; HbsAg+; HbeAg+; anti-Hbe antibody negative at the time of screening ≥6 months; quantifiable serum HBV DNA levels of >1.4 × 10^5^ copies/mL; ALT levels >1.5 times ULN and <10 times UNL at screening and ≥ 3 months; liver biopsy proven HBV ≥12 months of inclusion. And (vi) Exclusion: Hepatitis C, D, or HIV; decompensated liver disease; evidence of liver disease due to other etiology; serum creatinine >1.5 times ULN; hemoglobin <10 g/dL; platelet count less than 70,000/mm^3^; white-cell count <3,000/mm3; serious concurrent medical illnesses. | Mean age 31 years. Men 88%. All subjects were treatment naïve. Cirrhosis 16%. | Hybrid capture assay (Digene) Detection limit = 1.4 × 105 copies/mL. | Allocation concealment: adequate Open-label Pathologist blinded Intent-to-treat analyses: yes Study withdrawals adequately described: yes Funding: not reported
Santantonio, 2002^70^ Italy | Interferon-α 5 MU 3 times/week plus Lamivudine 100 mg × 52 weeks (n=24) Lamivudine 100 mg once daily (n=26) × 12 months | Inclusion: HBV DNA+; elevated ALT. All patients had a liver biopsy showing active disease within 24 months before admission to the study Exclusion: Decompensated liver cirrhosis, evidence of autoimmune hepatitis or markers of hepatitis C, D and HIV. | Mean age 45 years (range 25 to 63). Men 82%, All subjects were HbeAg-positive. Cirrhosis 32%. Prior HBV treatment: Interferon 42%. | PCR (Roche) Sensitivity of 400 copies/ml. | Allocation concealment: unclear Open-label Intent-to-treat analyses: yes Study withdrawals adequately described: none reported Funding: Authors stated they did not receive funding from pharmaceutical company involved with the drugs
D. Telbivudine ([underlined: L-nucleoside analog])
Versus adefovir (see above)
Versus lamivudine
Lai, 2007^71^ Multinational: Asia, Europe, North America, Australia, and New Zealand | Telbivudine 600 mg (n=680) Lamivudine 100 mg (n=687) × 52 weeks | Inclusion: Patients 16 to 70 years; HBeAg-positive or HbeAg-negative chronic hepatitis B (detectable serum HbsAg, serum ALT level 1.3 to 10 × ULN; serum HBV DNA level >6 log10 copies/mL; compatible pretreatment liver histologic findings. Exclusion: Coinfection with hepatitis C or D, or HIV; hepatic decompensation, pancreatitis, or HCC; previous treatment with nucleos(t)ide analogues; treatment with interferon or other immuno-modulators ≤12 months; other forms of liver disease; serum creatinine >1.5 mg/dL; serum amylase or lipase level >1.5 × ULN; serum albumin <3.3 g/dL deciliter; bilirubin level >2.0 mg/dL. Eligible patients with a serum α-fetoprotein level >50 ng/mL required exclusion of HCC. | Mean age 36 years (range 16 to 68). Mean ages for HbeAg-positive and HbeAg-negative were 33 and 43 years, respectively. Men 76%. Race: Asian 76%; white 15%; black <1%; other 9%. 68% subjects were HbeAg-positive and 32% HbeAg-negative. All subjects had not previously received a nucleosides or nucleotides. | PCR-DNA Cobas Amplicor (Roche) Detection limit = 300 copies per mL | Allocation concealment: unclear Double-blinded Pathologist blinded Intent-to-treat analyses: yes Study withdrawals adequately described: yes Funding: pharmaceutical
Lai 2005^72^ Gastroenterology Telbivudine Phase II Investigator Group | Telbivudine 400 mg (n=22) Telbivudine 600 mg (n=22) Telbivudine 400 mg plus Lamivudine 100 mg (n=21) Telbivudine 600 mg plus Lamivudine 100 mg (n=20) Lamivudine 100 mg (n=19 × 52 weeks | Inclusion: Ages 18 to 65 years; HbsAg seropositive ≥6 months; HbeAg seropositive at screening; serum HBV DNA level >6 log10 copies/mL; and serum ALT level 1.3 to 10 × ULN. Exclusion: Prior treatment with anti-HBV nucleos(t)ides; interferon treatment ≤12 months; HIV, hepatitis C or D; other known causes of liver disease; hepatic decompensation; history of pancreatitis; concurrent medical conditions that might confound safety or efficacy assessments during the study; history of alcohol or illicit substance abuse within ≤2 years. | Median ages ranged from 30 to 41 years (overall range was 18 to 68). Men 79%. Race: Asian 83%; white 8%; other 9% All subjects were HbeAg-positive and had not previously received a nucleosides or nucleotides. Prior HBV treatment: Interferon 4%. | PCR-DNA Cobas Amplicor (Roche) | Allocation concealment: unclear Double-blinded Intent-to-treat analyses: yes Study withdrawals adequately described: yes Funding: pharmaceutical
E. Entecavir monotherapy ([underlined: Acyclic guanosine derivative])
Chang, 2006^73^ Multinational: North America, Europe, Australia, Asia, South America | Entecavir 0.5 mg (n=357, 354 included in analyses) Lamivudine 100 mg (n= 358, 355 included in analyses) × 52 weeks | Inclusion: ≥16 years; HbeAg+ chronic hepatitis B and compensated liver function; a serum albumin level ≥3.0 g/dL; no history of variceal bleeding or hepatic encephalopathy); detectable HbsAg ≥24 weeks before screening; evidence of chronic hepatitis on a baseline liver-biopsy specimen obtained within 52 weeks before randomization. Exclusion: Coinfection with hepatitis C or D, or HIV; other forms of liver disease; use of interferon-α, thymosin α, or antiviral agents with activity against hepatitis B ≤24 weeks before randomization; prior lamivudine therapy lasting >12 weeks; α-fetoprotein level >100 ng/mL; history of ascites requiring diuretics or paracentesis; previous treatment with entecavir. | Mean age 35 years (≥16 at study entry). Men 76%. Race: Asian 57%; white 40%; black 2%. All subjects were HbeAg-positive and had not previously received a nucleoside analog. Prior HBV treatment: Interferon 13%. | PCR-DNA Cobas Amplicor (Roche) Detection limit = 300 copies per mL | Allocation concealment: unclear Double-blinded Pathologist blinded Intent-to-treat analyses: yes Study withdrawals adequately described: yes Funding: pharmaceutical
Lai, 200 ^74^ Multinational: North America, Europe, Australia, Asia, South America | Entecavir 0.5 mg (n=331, 325 included in analyses) Lamivudine 100 mg (n=317, 313 included in analyses) × 52 weeks | Inclusion: ≥16 years; HbeAg-chronic hepatitis B and compensated liver function; serum albumin level ≥3.0 g/dL; no history of variceal bleeding or hepatic encephalopathy; HbsAg ≥24 weeks before screening, evidence of chronic hepatitis on a baseline liver biopsy specimen obtained ≤52 weeks before randomization; evidence of HBV DNA by any commercial assay ≥2 weeks before screening; undetectable HbeAg, detectable anti-Hbe, serum HBV DNA level ≥ 0.7 Meq/mL; serum ALT level 1.3 to 10.0 × ULN. Exclusion: Coinfection with hepatitis C or D, or HIV; other forms of liver disease; use of interferon- α, thymosin α, or antiviral agents with activity against hepatitis B ≤24 weeks before randomization; prior lamivudine therapy >12 weeks; α-fetoprotein level >100 ng/mL; history of ascites requiring diuretics or paracentesis; previous treatment with entecavir. | Mean age 44 years (≥16 at study entry). Men 75%. Race: white 58%; Asian 39%; black 2%. All subjects were HbeAg-negative and had not previously received a nucleoside analog. Prior HBV treatment: Interferon 13%. | PCR assay (Roche). Detection limit = 300 copies per mL | Allocation concealment: unclear Double-blinded Intent-to-treat analyses: yes Study withdrawals adequately described: yes Funding: pharmaceutical
Sherman, 2006^75^ Multinational: North America, South America, Europe and the Middle East, Australia, and Asia | Entecavir 1 mg (n=147) continued Lamivudine 100 mg daily (n=146) × minimum of 52 weeks | Inclusion: ≥16 years; surface HbsAg+ men and women receiving ongoing lamivudine therapy and were refractory to that therapy; HbeAg+ and ALT levels 1.3 to 10 × ULN; HBV DNA levels ≥3.0 Meq/mL; compensated liver function; serum albumin ≥3.0 g/dL; no history of variceal bleeding, ascites requiring diuretics or paracentesis, or encephalopathy; evidence of chronic hepatitis upon liver biopsy that was performed at screening or ≤1 year prior to randomization and following clinical evidence of incomplete response to lamivudine. Exclusion: Hepatitis C or D, or HIV; other forms of liver disease; prior therapy with a nucleos(t)ide analogue with activity against HBV other than lamivudine for ≥12 weeks duration or given ≤6 months prior to randomization; interferon α or thymosin-a1 use ≤6 months prior to randomization; α-fetoprotein >100 ng/mL; prior treatment with entecavir. | Mean age 39years (range 16 to 74). Men 76%. Race: white 62%; Asian 37%. Subjects were HbeAg-positive and lamivudine resistant. Prior HBV treatment: Interferon 54%. | PCR assay (Roche). Detection limit = 300 copies per mL | Allocation concealment: adequate Double-blinded Pathologist blinded Intent-to-treat analyses: yes Study withdrawals adequately described: yes Funding: unclear
Chang, 2005^76^ Multinational: Australia, North America, Europe, Asia | Entecavir 1 mg (n=42) Entecavir 0.5 mg (n=47) Entecavir 0.1 mg (n=47) Lamivudine 100mg (n=45) Treatment: 24 to 52 weeks, plus 24 weeks followup. | Inclusion: Patients >16 years with chronic HBV infection considered to be lamivudine refractory on the basis of documented viremia after receiving ≥24 weeks of lamivudine therapy or documented evidence of a lamivudine resistance-associated substitution while receiving lamivudine. AST and ALT levels ≥10 × ULN and well-compensated liver function. Exclusion: Hepatitis C or D, or HIV; other form of liver disease or a liver transplant; received immuno-modulator therapy ≤24 weeks before randomization; received prior antiviral therapy. | Mean age 46 years. Men 81%. Race: white 61%; Asian 32%; black 2%. All subjects were lamivudine resistant. Prior HBV treatment: Interferon 45%. | PCR assay | Allocation concealment: adequate Double-blinded Intent-to-treat analyses: yes Study withdrawals adequately described: yes Funding: not reported
Lai 2002^77^ Multinational: Australia, North America, Europe, Asia | Entecavir 0.01 mg od (n=54) Entecavir 0.1 mg od (n=36) Entecavir 0.5 mg od (n=46) Lamivudine 100mg od (n=41) × 24 weeks | Inclusion: HbsAg+ for 24 weeks or more; either HbeAg+ or HbeAg-, but anti-Hbe+ for 12 weeks or more before randomization; HBV DNA ≥40 MEQ/mL; baseline ALT ≤10 × ULN (patients with normal ALT were not excluded); well-compensated liver disease. Exclusion: Immunosuppressive therapy; IFN-α, thymosin-α, or nucleoside analogues ≤24 weeks of randomization; hepatitis C or D or HIV; serious medical illnesses; evidence of pancytopenia, alcohol or other drug abuse. | Mean age 31 years (range). Men 74%. Race: Asian 57%; white 32%; other 11%. | PCR-DNA Amplicor (Roche) and Quantiplex | Allocation concealment: adequate Double-blinded Intent-to-treat analyses: no Study withdrawals adequately described: yes Funding: several authors noted as receiving support from pharmaceutical
F. Combination Pegylated Interferon-α-2a and Lamivudine therapy ([underlined: Interferon])
Lau, 2005^56^ | See under lamivudine monotherapy
Marcellin, 2004^57^ | See under lamivudine monotherapy
G. Combination Pegylated interferon-α-2b and Lamivudine therapy ([underlined: Interferon])
Chan, 2005^59^ | See under lamivudine combination therapy
Janssen, 2005^78^ Multinational | Pegylated interferon-α-2b 100microg/week plus lamivudine 100 mg (n=130) Pegylated interferon-α-2b and placebo (n=136) × 52 weeks, plus 26 weeks followup. | Inclusion: 16 years or older; HbsAg+ >6 months; positive for HbeAg on 2 occasions within 8 weeks before randomization; 2 episodes of raised serum concentrations of ALT (× 2 ULN) ≤8 weeks before randomization Exclusion: Serum antibodies against hepatitis C or D, or HIV; antiviral therapy or immunosuppressive therapy ≤ preceding 6 months; substance abuse ≤ previous 2 years; other acquired or inherited causes of liver disease; coexisting serious medical or psychiatric illness; uncontrolled thyroid disease; evidence of HCC; advanced liver; history of ascites, variceal bleeding, or hepatic encephalopathy. | Mean age 35 years (≥ 6 at study entry). Men 77%. Race: white 74%; Asian 20%; other 6%. All subjects were HbeAg-positive. | PCR assay based on the Eurohep standard | Allocation concealment: unclear Double-blinded Pathologist blinded Intent-to-treat analyses: yes (one dose) Study withdrawals adequately described: yes Funding: pharmaceutical
H. Interferon-α-2b and Lamivudine ([underlined: Interferon])
Shi, 2006^62^ | See under lamivudine
Economou, 2005^63^ | See under lamivudine
Akarca, 2004^64^ | See under lamivudine
Yalcin 2003^79^ Turkey | Interferon-α-2b 10 MU 3 times/ week (n=17) × 52 weeks | Inclusion: Ages 18 to 60 years; positive HBsAg, and HBeAg; HBV DNA by liquid hybridization or PCR; elevated serum ALT level 11.5–10 × ULN on 3 occasions during the 6 months before enrollment; liver biopsy demonstrated histologic evidence of chronic HBV infection. Exclusion: Treated previously with IFN or had received antiviral or immunosuppressive medications; hepatitis C or D, or HIV; other causes of chronic liver disease; if they drank 140 g of alcohol per day; HCC; decompensated liver disease; history of ascites, variceal hemorrhage, or hepatic encephalopathy; any contraindications specified for use of IFN. | Mean age 25 years. Men 69% | Hybridization assay (Digene) Detection limit = 2.8 × 10^5^ copies/mL | Allocation concealment: unclear Open-label Pathologist blinded Intent-to-treat analyses: no Study withdrawals adequately described: yes Funding: not reported
Jang, 2004^65^ | See under lamivudine
Schiff, 2003^47^ | See under lamivudine
Barbaro, 2001^66^ | See under lamivudine
Schalm, 2000^67^ | See under lamivudine
Mutimer 1998^80^ | Interferon-α-2b 10 MU 3 times/ week plus placebo × 4 weeks then lamivudine 100 mg × 12 weeks (n=6) Interferon-α-2b 10 MU 3 times/ week plus lamivudine 100 mg × 16 weeks (n=14) × 16 weeks, plus 16 weeks followup. | Inclusion: Ages 18–70; compensated liver disease; HBsAg, HBeAg and HBV DNA positive; failed to seroconvert (from HBeAg to anti-HBe) with at least one prior course of interferon at a minimum dose of 13.5 mega units per week ≥16 weeks; ≥6 months since the most recent interferon treatment. Exclusion: Co-infection with hepatitis D or C virus or HIV. | Mean age 39 years. Men 95%. Race: white 65%; Asian 35%. All subjects were interferon-α resistant. Cirrhosis 10%. | Real-time PCR assay (Roche) Detection limit = 1 × 103 copies per mL | Allocation concealment: adequate Double-blinded Intent-to-treat analyses: yes Study withdrawals adequately described: yes Funding: not reported
I. Pegylated interferon-α-2b versus Interferon-α-2b
Zhao, 2007^81^ China multicenter study | Pegylated interferon-α-2b (1.0 mg/ kg once per week; (n=115) Interferon-α-2b (3 MIU 3 times/ week (n=115) × 24 weeks, plus 24 weeks followup. | Inclusion: Age 18 to 70 years; HBsAg and HBeAg ≥6 months prior to enrollment; serum HBV DNA level >1 ×10^5^ copies/mL; and ALT level 2 to 10 × ULN. Exclusion: Any cause of liver disease other than chronic HBV infection; use of immune regulators during the previous 6 months, or individuals who have received antiviral therapy (nucleotide analogues and IFN) during the previous 3 months of the commencement of the study. | Median age 31 years. Men 82%. Race: Asian 100% Prior HBV treatment: Interferon 13%. | Real-time PCR assay (Roche) Detection limit = 1 × 103 copies per mL | Allocation concealment: adequate Open-label Intent-to-treat analyses: yes Study withdrawals adequately described: yes Funding: not reported
J. Interferon-α-2b
Chung, 2003^82^ South Korea | “Individualized” Interferon-α-2b 5 MU 3 times/week (treatment duration varied) (n=30) Interferon-α-2b × 6 months (n=35) | Inclusion: Age ≥18 years; of HBsAg in serum ≥ 6 months with or without HBeAg; positive serum HBV-DNA; and serum ALT levels elevated >2 ULN >6 months before entry. Exclusion: mild activity and cirrhosis; serum bilirubin >2.0 mg/dl; serum albumin <3 g/dl; serum creatinine concentration >1.4 mg/dl; history of ascites or variceal hemorrhage; positive serum anti-hepatitis C or D. | Mean age 35 years (range). Men 88%. Race: Asian 100% | Liquid hybridization assay (Abbott) Detection limit = 1.6 pg/ml. | Allocation concealment: unclear Open-label Intent-to-treat analyses: not reported Study withdrawals adequately described: no withdrawals reported Funding: not reported
Janssen 1999^83^ | Prolonged therapy (16 weeks of further Interferon-α-2b (n=61) Standard therapy (no further Interferon-α-2b therapy) (n=57) | Inclusion: Ages 18 to 70 years; HBsAg positivity in serum ≥6 months; presence of HBeAg and HBV DNA in serum; elevation of either serum AST or ALT values ≥3 occasions in the 3 months before entry; histological evidence of chronic hepatitis on a liver biopsy taken in the 6 months preceding enrollment. Exclusion: Hepatitis C or D, or HIV; recent alcohol abuse or drug addiction; previous IFN-a course ≥12 weeks using at least 30 million units (MU) per week; any antiviral or immune modulatory therapy in the preceding 6 months; immuno-compromised patients; history of either ascites, bleeding esophageal varices, and hepatic encephalopathy. | Mean age 34 years (range 16 to 70). Men 75%. Race: white 80%; Asian 14%; other 6% Cirrhosis 17% | Hybridization (Genostics, Abbott Laboratories). Cut-off = 1.7pg/mL | Allocation concealment: adequate Open-label Pathologist blinded Intent-to-treat analyses: yes Study withdrawals adequately described: yes Funding: pharmaceutical
Lampertico 1997^84^ | interferon-α-2b 6 MU 3 times/ week × 24 consecutive months (n=21) No therapy (n= 21) | Inclusion: Ages 18 to 65 years; presence of HBsAg and anti-HBe in serum ≥1 year: serum ALT levels >2 the ULN; HBV DNA either persistently or intermittently detectable by dot-blot assay on serum samples taken at 3-month intervals during year before enrollment; histologically documented chronic active hepatitis with or without cirrhosis. Exclusion: History of hepatic decompensation; hepatitis C or D and HIV; drug abuse, alcoholism; antiviral or immunosuppressive therapy in the previous 12 months | Mean age 46 years. Men 86%. Cirrhosis 17% | Dot-blot hybridization | Allocation concealment: unclear Open-label Intent-to-treat analyses: yes Study withdrawals adequately described: yes Funding: private
Lopez-Alcorocho 1997^85^ | Interferon-α-2b 10 MU (3 times/ week) × 2 months then 5 MU × 2 months then 10 MU × 2 months (n=19) Interferon-α-2b 10 MU (3 times/ week) × 2 months then 5 MU × 2 months then 10 MU × 8 months (n=19) 52 weeks followup | Inclusion: HBsAg+; elevated ALT; histologically confirmed disease. Exclusion: Hepatitis C or D and HIV. | Mean age 34 years (range 20–64). Men 87%. Intrafamilial exposure 16%. All subjects treatment-naïve. | Radioimmunoassay | Allocation concealment: unclear Open-label Intent-to-treat analyses: yes Study withdrawals adequately described: yes Funding: foundation
Di Bisceglie, 1993^86^ United States | Interferon-α-2b 10 MU (3 times/ week) × 16 weeks (n=25) No therapy (n= 22) 6 month study duration | Inclusion: Elevated AST ≥6 months; HBeAg, HBsAg and HBV DNA+. Exclusion: Hepatitis D and HIV; decompensated liver disease | Mean age 44 years (range 23–72). Men 77%. Race: white 98%. Cirrhosis 38% | Quantitative liquid phase hybridization (Genostics, Abbott). | Allocation concealment: adequate Intent-to-treat analyses: yes Study withdrawals adequately described: yes Funding: not reported
Műller 1990a^87^ Germany | Interferon-α-2b 3 MU 3 times/ week × 4 months (n=25) No treatment (n=25) 26 weeks followup | Inclusion: Evidence of chronic hepatitis; seropositive for HBsAg and HBVDNA >6 months. Exclusion: Hepatitis D and HIV; decompensated cirrhosis; chronic renal insufficiency, or those requiring hemodialysis or immunosuppressive therapy; patients with previous organ transplantations or considered to be of poor general condition. | Mean age 41 years (range 18–65). Men 79%. Cirrhosis 44% | Spot molecular and solution hybridization | Allocation concealment: unclear Intent-to-treat analyses: ongoing Study withdrawals adequately described: not reported Funding: not reported
Hadziyannis 1990^88^ Greece | Interferon-α-2b 2 MU 3 times/week × 14 to 16 weeks (n=25; 17 have finished this ongoing study). Untreated controls (n=25) | Inclusion: HBsAg+; HBeAg- and HBV DNA+ >1 year; anti-HDV, anti-HIV. Exclusion: Decompensated cirrhosis; received therapy with corticosteroids, immunosuppressive drugs or antiviral agents ≤6 months | Mean age 49 years (range 26–66). Men 94% Cirrhosis 44% | Spot molecular hybridization (Genostics) | Allocation concealment: unclear Open-label Intent-to-treat analyses: ongoing Study withdrawals adequately described: no withdrawals reported Funding: not reported
Waked 1990^89^ | Interferon-α-2b 5 MU 3 times/ week × 16 weeks (n=12) Interferon-α-2b 5 MU 3 times/ week × 16 weeks (n=12) 52 weeks followup | Inclusion: HBsAg+, and HBeAg+ ≥6 months; elevated ALT; histologically confirmed disease; compensated liver disease. Exclusion: Chronic persistent hepatitis (biopsy); inactive cirrhosis; serum albumin >3 gm/dL; serum bilirubin >4 gm/dL; serum creatinine concentration >1.5 mg/dl; history of ascites or variceal hemorrhage; corticosteroid or antiviral therapy ≤12 months. | Mean age 36 years (range 9–62). Men 78%. Cirrhosis 44% | Enzyme linked immunoassay | Allocation concealment: unclear Open-label Intent-to-treat analyses: no Study withdrawals adequately described: yes Funding: not reported
K. Interferon-α-2b plus prednisolone
Reichen 1994^90^ Switzerland | Arm A prednisone 50 mg for 2 weeks followed by 25 mg for another 2 weeks. After 2 week drug-free interval, recombinant Interferon-α-2b 1.5 MU for 4 months (n=18) Arm B Same regimen w/ placebo replacing prednisone and followed by Interferon-α-2b 1.5 MU (n=19) Arm C Same regimen w/ placebo replacing prednisone and followed by Interferon-α-2b at 5 MU (n=19) | Inclusion: 18–70 years; ALT ≥2 × ULN; replicating HBV documented for at least 6 months; chronic active HBV by biopsy no older than 3 months at study entry; positive for HBsAg and HBeAg. Exclusion: Lack of histological activity; alcohol abuse; spontaneous seroconversion during workup; suspicion of autoimmune liver disease; HIV+; alcohol consumption >80 g/day for men & 50 g/day for women; drug abuse; decompensated cirrhosis; HCC; previous Interferon therapy and immunosuppressive therapy within preceding 6 months. | Mean age 40 years. Male: 85% | Hybridization | Allocation concealment: adequate Blinding: unclear although study placebo-controlled Pathologist blinded Intent-to-treat analyses: no Study withdrawals adequately described: no Funding: not reported
Zarski 1994^91^ France | Interferon α-2b 5 MU 3 times/ week × 24 weeks (n=25) Interferon-α-2b plus prednisolone, 60, 40, 20 mg × 6 weeks (n=31) | Inclusion: 18 to 75 years; serum HBsAg+ ≥6 months; HBeAg and HBV DNA+ documented on 3 or more occasions at last 1 month apart ≤6 months before entry; elevated ALT on at least 3 occasions before entry, with an average value ≥1.5 × ULN; compensated liver disease; evidence of HBV on biopsy. Exclusion: Corticosteroid or antiviral therapy ≤12 months; other serious medical illnesses that might preclude completion of the study; alcohol or drug abuse or other potential causes of liver disease; seropositivity for anti-hepatitis C or D or HIV type I and II. | Mean age 38 years. Male: 89% | Direct-spot hybridization | Allocation concealment: unclear Pathologist blinded Intent-to-treat analyses: yes Study withdrawals adequately described: no withdrawals reported Funding: pharmaceutical
Perez 1993^92^ Argentina | Prednisone 60, 40, 20 mg daily every 2 weeks, then 2 weeks' rest then interferon α-2b 10 MU 3 times/ week × 16 weeks (n=26) No treatment × 24 weeks then interferon α-2b (n=24) × 24 weeks | Inclusion: Documented HBeAg and HBV-DNA positive ≥6 months, serum ALT activities ≥1 to 5 × ULN; liver biopsy specimens compatible with chronic hepatitis. Exclusion: Other causes of liver disease (other than CHB) were excluded. | Not reported | | Allocation concealment: unclear Open-label Intent-to-treat analyses: yes Study withdrawals adequately described: yes Funding: not reported
Lok 1992^93^ China | Prednisone, 45, 30, and 15 mg each for 2 weeks, then 2 weeks rest Interferon-α-2b 10 MU 3 times/ week × 16 weeks (n=21) Matching placebo then 2 weeks rest then Interferon α-2b 10 MU 3 times weekly × 16 weeks (n=18) No treatment (n=16) | Inclusion: 18–60 years; presence of HBsAg in serum >6 months; HBeAg+; HBV DNA+; stable serum HBV DNA and ALT levels on at least 3 occasions, 1 month apart, during the 6 months of entry. Exclusion: Decompensated liver disease; coagulopahy precluding liver biopsy; severe systemic illness; immunosuppressive or antiviral therapy within preceding 12 months; presence of other factors that may contribute to liver disease, such as alcoholism and seropositivity for antibody to hepatitis D or HIV. | Mean age 28 years (range). Men 62%. Race: Asian 100%. Cirrhosis 10% | Direct spot hybridization. Sensitivity of the assay 0.2pg HBV DNA/20uL serum. | Allocation concealment: unclear Blinding not stated Pathologist blinded Intent-to-treat analyses: ongoing Study withdrawals adequately described: yes Funding: pharmaceutical and other
Niederau 1992^94^ Germany | Arm A Prednisone, 40 and 20 mg for 2 weeks, then Interferon-α-2b 2 MU 3 times/ week × 3 months (n=20). If no seroconversion Interferon-α-2b 5 MU given. Arm B Interferon-α-2b 5 MU 3 times/ week × 4 months (n=20) Arm C No treatment (n=20) | Exclusion: absence of HBeAg or HBV DNA in serum; AST below required value; antibody to hepatitis D or HIV; thrombocytopenia; advanced cirrhosis; alcohol or drug abuse | Mean age 43 years. Men 91%. | Solution hybrid assay (Abbott) | Allocation concealment: unclear Open-label Intent-to-treat analyses: yes Study withdrawals adequately described: yes Funding: pharmaceutical
Perez 1990^95^ | Prednisone 60, 40, 20 mg daily every 2 weeks, then 2 weeks' rest then interferon α-2b 10 MU 3 times/ week × 16 weeks (n=17) No treatment × 24 weeks then interferon α-2b (n=18) × 24 weeks | Inclusion: ≥18 years; presence of serum HBsAg, HBeAg, HBV DNA ≥6 months; ALT ≥1.3 × ULN on at least 3 occasions; compensated liver disease. Exclusion: Seropositivity for antibody to hepatitis D or HIV; inadequate hematocrit, platelet, white blood cell and granulocyte counts. | Mean age 39 years. Men 77%. | Molecular hybridization | Allocation concealment: unclear Open-label Intent-to-treat analyses: yes Study withdrawals adequately described: yes Funding: not reported
Perillo 1990^96^ United States | Arm A Prednisone, 60, 40, 20, 0 mg each, for 2 weeks at each dose) followed by Interferon-α-2b 5 MU daily × 16 weeks (n=44) Arm B Placebo plus Interferon-α-2b 5 MU daily × 16 weeks (n=41) Arm C Placebo plus Interferon-α-2b 1 MU daily × 16 weeks (n=41) Arm D No treatment (n=43) | Inclusion: ≥18 years; presence of HBsAg in serum ≥6 months; HBeAg+; HBV DNA+; stable serum HBV DNA and ALT levels on at least 3 occasions; ALT ≥1.3 × ULN on at least 3 occasions; compensated liver disease. Exclusion: Immunosuppressive or antiviral therapy within preceding 12 months; serious medical illness; low hematocrit, platelet and granulocyte counts; elevated serum creatinine; alcoholism or drug abuse; and seropositivity for antibody to hepatitis D or HIV. | Mean age 40 years. Men 85%. | Solution hybrid assay (Abbott) | Allocation concealment: unclear Partially double-blinded Pathologist blinded Intent-to-treat analyses: yes Study withdrawals adequately described: yes Funding: Government, pharmaceutical

* Either coinfection or presence of antibodies

Table E3 Reported clinical and intermediate outcomes after comparisons of antiviral drugs for chronic hepatitis B (randomized controlled clinical trials)

Treatments | Mortality/Liver-related Mortality | HCC | Cirrhosis | Liver Failure | Combined | Biochemical | Virological (DNA; HBe or HBs Ag Status) | Histological | Harm Effects
Adefovir dipivoxil+lamivudine vs. adefovir dipivoxil | | | | | | 2 studies^43,45^ | 2 studies^43,45^ | | 1 study^43^
Adefovir dipivoxil+lamivudine vs. lamivudine | | | | | | 2 studies^43,58^ | 2 studies^43,58^ | | 2 studies^43,58^
Adefovir dipivoxil (dose, time) | 1 study^97^ | 1 study^97^ | | | | 4 studies^40,^,^42,^,^44,98^ | 5 studies^40,^,^42,^,^44,^,^97,98^ | 3 studies^42,^,^97,98^ | 6 studies^40,^,^42,^,^44,97^–^99^
Adefovir dipivoxil vs. placebo | | | | | | 4 studies^40^–^42,98^ | 5 studies^40^–^42,^,^98,100^ | 3 studies^41,^,^42,98^ | 5 studies^40^–^42,^,^98,99^
Entecavir (dose, time) | 1 study^76^ | | | | 2 studies^76,77^ | 2 studies^76,77^ | 2 studies^76,77^ | | 2 studies^76,77^
Entecavir vs. lamivudine | 5 studies^73^–^76,101^ | | | 2 studies^73,101^ | 4 studies^73,75^–^77^ | 7 studies^73^–^77,101^ | 6 studies^73^–^77,101^ | 3 studies^73^–^75^ | 6 studies^73^–^77,101^
Interferon alfa-2b+corticosteroid vs. interferon alfa-2b | 1 study ^90^ | | 1 study ^91^ | | | 4 studies^90,^,^92,^,^95,96^ | 8 studies^90^–^96,102^ | 2 studies ^90,91^ | 3 studies^92,^,^93,95^
Interferon alfa-2b+corticosteroid vs. no treatment | | | | | | 1 study^96^ | 3 studies^93,^,^94,96^
Interferon alfa-2b+corticosteroid vs. symptomatic treatment | 1 study^103^ | | | | | 1 study^103^ | 1 study^103^ | | 1 study^103^
Interferon alfa-2b+lamivudine | | | | | 2 studies^61,79^ | 2 studies^67,79^ | 3 studies^67,^,^79,104^ | 2 studies^67,79^ | 2 studies^67,79^
(dose, time) | | | | | | ^80^ | ^80^
Interferon alfa-2b+lamivudine vs. lamivudine | | | | | 5 studies^60,^,^61,^,^64,^,^66,68^ | 8 studies^47,62^–^67,69^ | 10 studies^47,^,^60,62^–^66,^,^68,^,^69,104^ | 7 studies^47,^,^60,^,^64,66^–^69^ | 10 studies^47,^,^60,62^–^69^
Interferon alfa-2b+lamivudine vs. placebo | | | | | | 1 study^47^ | 2 studies^47,104^ | 1 study^47^ | 1 study^47^
Interferon alfa-2b+placebo vs. lamivudine | | | | | | 1 study^67^ | 1 study^67^ | 1 study^67^ | 1 study^67^
Interferon alfa-2b+placebo vs. no treatment | | | | | | | 1 study^93^
Interferon alfa-2b (dose, time) | 2 studies^85,90^ | | | | 1 study^85^ | 4 studies^82,^,^85,^,^90,96^ | 4 studies^82,^,^85,^,^90,96^ | | 2 studies^82,85^
Interferon alfa-2b vs. lamivudine | | | | | | | ^104^
Interferon alfa-2b vs. no treatment | 1 study^89^ | 1 study^84^ | 1 study^89^ | | 4 studies^84,^,^87,^,^88,105^ | 4 studies^83,^,^84,^,^86,96^ | 7 studies^83,^,^84,^,^86,^,^94,^,^96,104^ | 2 studies^84,89^ | 5 studies^83,^,^84,^,^86,^,^87,105^
Lamivudine vs. adefovir dipivoxil | | | | | | 1 study^43^ | 1 study^43^ | | 1 study^43^
Lamivudine vs. baseline | | | | | | 2 studies^106,107^ | 4 studies^56,^,^57,^,^106,107^ | 1 study^107^
Lamivudine (dose, time) | | | | | | 3 studies^50,^,^55,108^ | 4 studies^50,108^–^110^ | 3 studies^50,^,^107,111^ | 4 studies^50,^,^55,^,^108,110^
Lamivudine vs. no treatment | | | | 1 study^54^ | | 1 study^54^ | 1 study^54^
Lamivudine vs. placebo | 1 study^51^ | | | 1 study^51^ | 3 studies^46,^,^49,51^ | 7 studies^46^–^48,^,^50,^,^108,^,^112,113^ | 11 studies^48^–^50^10861652^46,^,^47,^,^51,^,^104,^,^110,^,^112,113^ | 6 studies^46^–^48,^,^50,^,^111,113^ | 9 studies^46^–^51,^,^108,^,^110,112^
Lamivudine vs. telbivudine | | | | | 1 study^72^ | 1 study^72^ | 1 study^72^ | | 1 study^72^
Lamivudine vs. usual care | | | | | | | 1 study^53^
Peginterferon alfa-2a+ lamivudine vs. baseline | | | | | | | 2 studies^56,57^
Peginterferon alfa-2a+ lamivudine vs. interferon alfa-2b | | | | | 1 study^114^
Peginterferon alfa-2a+ lamivudine vs. lamivudine | 1 study^56^ | | | | 4 studies^56,^,^57,^,^114,115^ | 2 studies^56,57^ | 2 studies^56,57^ | 2 studies^56,57^ | 2 studies^56,57^
Peginterferon alfa-2a+ lamivudine vs. peginterferon alfa-2a | 1 study^56^ | | | | 1 study^56^ | 1 study^56^ | 1 study^56^ | 1 study^56^ | 1 study^56^
Peginterferon alfa-2a+ placebo vs. baseline | | | | | | | 1 study^56^
Peginterferon alfa-2a+ placebo vs. lamivudine | 1 study^56^ | | | | 3 studies^56,^,^57,114^ | 2 studies^56,57^ | 2 studies^56,57^ | 2 studies^56,57^ | 2 studies^56,57^
Peginterferon alfa-2a vs. baseline | | | | | | | 1 study^57^
Peginterferon alfa-2a vs. lamivudine | | | | | 1 study^114^
Peginterferon alfa-2a (dose, time) | | | | | 1 study^116^ | 1 study^116^ | 1 study^116^ | | 1 study^116^
Peginterferon alfa-2b+ lamivudine vs. lamivudine | 1 study^117^ | | | 1 study^117^ | | 2 studies^59,117^ | 3 studies^59,^,^117,118^ | 1 study^59^ | 1 study^59^
Peginterferon alfa-2b+ lamivudine vs. peginterferon alfa-2b | | | | | | 4 studies^78,119^–^121^ | 6 studies^78,120^–^124^ | 2 studies^78,125^ | 2 studies^78,119^
Peginterferon alfa-2b vs. interferon alfa-2b | | | | | 1 study^81^ | 1 study^81^ | 1 study^81^ | | 1 study^81^
Telbivudine+lamivudine vs. lamivudine | | | | | 1 study^72^ | 1 study^72^ | 1 study^72^ | | 1 study^72^
Telbivudine+lamivudine vs. telbivudine | | | | | 1 study^72^ | 1 study^72^ | | | 1 study^72^
Telbivudine vs. adefovir dipivoxil | | | | | | 1 study^44^ | 1 study^44^ | | 1 study^44^
Telbivudine vs. lamivudine | | | | | 1 study^71^ | 1 study^71^ | 1 study^71^ | 1 study^71^ | 1 study^71^
Telbivudine (dose, time) | | | | | | 2 studies^72^ | | | 1 study^72^

Table E4 Evidence tables of the effects of antiviral drugs on patient outcomes (individual randomized controlled clinical trials)

Author Active Intervention, Daily/Weekly Dose Length of Intervention | Control Intervention, Daily/Weekly Dose Length of Intervention | Outcome | Time to Measure Outcomes from Randomization (weeks) After Active/Control Treatments | Cases/Randomized | Rate of Outcomes after Active/Control Treatment (%) | Relative Risk (95% CI) | Risk Difference (95% CI) | Number Needed to Treat
(A) Outcomes after antiviral drug therapy Interferon administration
Niederau, 1992^94^ Interferon-alpha (Intron A, Essex), 1/2 MU 3 times /week increasing to 5 MU in patients in whom therapy did not eliminate HBeAg and HBVDNA during 2 months of therapy Prednisolone, 2 weeks 40 mg/day and further 2 weeks 20 mg/day, 16 weeks | Interferon-alpha (Intron A, Essex), 2/5 MU 3 times per week, 16 weeks | Loss of HBV DNA | 16/16 | 5/20 9/20 | 25/45 | 0.56 (0.23; 1.37) | -0.20 (-0.49; 0.09) | -5
No treatment, 0, 16 weeks | Loss of HBV DNA | 16/16 | 5/20 0/14 | 25/0 | 7.86 (0.47; 131.58) | 0.25 (0.04; 0.46) | 4
Niederau, 1992^94^ Interferon-alpha (Intron A, Essex), 2/5 MU 3 times a week, 16 weeks | No treatment, 0, 16 weeks | Loss of HBV DNA | 16/16 | 9/20 0/14 | 45/0 | 13.57 (0.85; 215.62) | 0.45 (0.22; 0.68) | 2
Niederau, 1992^94^ Interferon-alpha (Intron A, Essex), 1/2 MU 3 times per week with increasing to 5 MU in patients in whom therapy did not eliminate HBe-Ag and HBV-DNA 2 months after its prednisolone, 2 weeks 40 mg/day and further 2 weeks 20 mg/day, 16 weeks | Interferon-alpha (Intron A, Essex), 2/5 MU 3 times per week, 16 weeks | Reduction in HBV DNA | 16/16 | 10/20 10/20 | 50/50 | 1.00 (0.54; 1.86) | 0.00 (-0.31; 0.31)
| Interferon-alpha (Intron A, Essex), 2/5 MU 3 times per week, 16 weeks | Unchanged HBV DNA | 16/16 | 5/20 1/20 | 25/5 | 5.00 (0.64; 39.06) | 0.20 (-0.01; 0.41) | 5
| Interferon-alpha (Intron A, Essex), 2/5 MU 3 times per week, 16 weeks | HBeAg negative | 16/16 | 4/20 8/20 | 20/40 | 0.50 (0.18; 1.40) | -0.20 (-0.48; 0.08) | -5
| Interferon-alpha (Intron A, Essex), 2/5 MU 3 times per week, 16 weeks | HBeAg positive | 16/16 | 16/20 12/20 | 80/60 | 1.33 (0.88; 2.03) | 0.20 (-0.08; 0.48) | 5
| Interferon-alpha (Intron A, Essex), 2/5 MU 3 times per week, 16 weeks | HBsAg negative | 16/16 | 1/20 0/20 | 5/0 | 3.00 (0.13; 69.52) | 0.05 (-0.08; 0.18) | 20
| Loss of HBV DNA | 40/40 | 5/20 9/20 | 25/45 | 0.56 (0.23; 1.37) | -0.20 (-0.49; 0.09) | -5
No treatment, 0, 16 weeks | Loss of HBV DNA | 40/40 | 5/20 1/14 | 25/5 | 3.50 (0.46; 26.80) | 0.18 (-0.05; 0.41) | 6
Niederau, 1992^94^ Interferon-alpha (Intron A, Essex), 2/5 MU 3 times a week, 16 weeks | No treatment, 0, 16 weeks | Loss of HBV DNA | 40/40 | 9/20 1/14 | 45/5 | 6.30 (0.90; 44.27) | 0.38 (0.12; 0.63) | 3
Niederau, 1992^94^ Interferon-alpha (Intron A, Essex), 1/2 MU 3 times per week with increasing to 5 MU in patients in whom therapy did not eliminate HBe-Ag and HBV-DNA 2 months after its prednisolone, 2 weeks 40 mg/day and further 2 weeks 20 mg/day, 16 weeks | Interferon-alpha (Intron A, Essex), 2/5 MU 3 times per week, 16 weeks | Reduction in HBV DNA | 40/40 | 10/20 10/20 | 50/50 | 1.00 (0.54; 1.86) | 0.00 (-0.31; 0.31)
No treatment, 16 weeks | Reduction in HBV DNA | 40/40 | 10/20 2/14 | 50/15 | 3.50 (0.90; 13.58) | 0.36 (0.07; 0.64) | 3
Niederau, 1992^94^ Interferon-alpha (Intron A, Essex), 2/5 MU 3 times a week, 16 weeks | No treatment, 16 weeks | Reduction in HBV DNA | 40/40 | 10/20 2/14 | 50/15 | 3.50 (0.90; 13.58) | 0.36 (0.07; 0.64) | 3
Niederau, 1992^94^ Interferon-alpha (Intron A, Essex), 1/2 MU 3 times per week with increasing to 5 MU in patients in whom therapy did not eliminate HBe-Ag and HBV-DNA 2 months after its prednisolone, 2 weeks 40 mg/day and further 2 weeks 20 mg/day, 16 weeks | Interferon-alpha (Intron A, Essex), 2/5 MU 3 times per week, 16 weeks | Unchanged HBV DNA | 40/40 | 5/20 1/20 | 25/5 | 5.00 (0.64; 39.06) | 0.20 (-0.01; 0.41) | 5
No treatment, 0, 16 weeks | Unchanged HBV DNA | 40/40 | 5/20 11/14 | 25/80 | 0.32 (0.14; 0.71) | -0.54 (-0.82; -0.25) | -2
Niederau, 1992^94^ Interferon-alpha (Intron A, Essex), 2/5 MU 3 times a week, 16 weeks | No treatment, 16 weeks | Unchanged HBV DNA | 40/40 | 1/20 11/14 | 5/80 | 0.06 (0.01; 0.44) | -0.74 (-0.97; -0.50) | -1
Robson, 1992^103^ Interferon alpha-2b (Intron A; Scherag), 4 10MI 3 times/week after 6 weeks of prednisone and 2 weeks without treatment Prednisone, 60mg/day for 2 weeks then 40mg/day for 2 weeks, and then 20mg/day for 2 weeks, 24 weeks | Symptomatic treatment, 24 weeks | Death | 72/72 | 0/10 1/10 | 0/10 | 0.33 (0.02; 7.32) | -0.10 (-0.34; 0.14) | -10
| Symptomatic treatment, 24 weeks | Leucopenia | 24/24 | 2/10 0/10 | 20/0 | 5.00 (0.27; 92.62) | 0.20 (-0.08; 0.48) | 5
| Symptomatic treatment, 24 weeks | HBeAg loss, undetectable HBV DNA | 24/24 | 6/10 1/10 | 60/10 | 6.00 (0.87; 41.21) | 0.50 (0.14; 0.86) | 2
HBsAg loss | 24/24 | 1/10 0/10 | 10/0 | 3.00 (0.14; 65.90) | 0.10 (-0.14; 0.34) | 10
Lok, 1992^93^ Interferon alpha-2b (IntronA; Schering Plough, Kenilworth, NJ), 4 /10 MU 3 times per week Prednisone, 1545, 30, and 15 mg each for 2 weeks, followed by a 2-week rest, 24 weeks | Placebo for 6 weeks + 2 weeks rest then Interferon alpha 2b, 4 /10 MU 3 times per week, 24 weeks | Development of Interferon-neutralizing antibody | 48/48 | 4/40 1/39 | 10/3 | 3.90 (0.46; 33.36) | 0.07 (-0.03; 0.18) | 13
No treatment, 24 weeks | Partial antiviral response: sustained clearance of serum HBV DNA by direct spot hybridization (lower limit of detection of 10 pg/mL) and clearance of HBeAg but not HBsAg | 48/48 | 9/40 3/36 | 22/8 | 2.70 (0.79; 9.21) | 0.14 (-0.02; 0.30) | 7
Lok, 1992^93^ Interferon alpha 2b, 4/10 MU 3 times per week Placebo, 15 weeks Placebo for 6 weeks + 2 weeks rest, 24 weeks | No treatment, 24 weeks | Partial antiviral response: sustained clearance of serum HBV DNA by direct spot hybridization (lower limit of detection of 10 pg/mL) and clearance of HBeAg but not HBsAg | 48/48 | 6/39 3/36 | 15/8 | 1.85 (0.50; 6.84) | 0.07 (-0.07; 0.22) | 14
Lok, 1992^93^ Interferon alpha-2b (IntronA; Schering Plough, Kenilworth, NJ), 4 /10 MU 3 times per week Prednisone, 30, and 15 mg each for 2 weeks, followed by a 2-week rest, 24 weeks | Placebo for 6 weeks + 2 weeks rest then Interferon alpha 2b, 4 /10 MU 3 times per week, 24 weeks | Partial antiviral response: sustained clearance of serum HBV DNA by direct spot hybridization (lower limit of detection of 10 pg/mL) and clearance of HBeAg but not HBsAg | 48/48 | 9/40 6/39 | 22/15 | 1.46 (0.57; 3.72) | 0.07 (-0.10; 0.24) | 14
No treatment, 24 weeks | Complete antiviral response: sustained clearance of serum HBV DNA by direct spot hybridization (lower limit of detection of 10 pg/mL) and clearance of HBeAg and HBsAg | 48/48 | 0/40 0/36 | | | 0.00 (-0.05; 0.05)
Lok, 1992^93^ Interferon alpha 2b, 4/10 MU three times per week Placebo for 6 weeks +2 weeks rest, 24 weeks | No treatment, 24 weeks | Complete antiviral response: sustained clearance of serum HBV DNA by direct spot hybridization (lower limit of detection of 10 pg/mL) and clearance of HBeAg and HBsAg | 48/48 | 2/39 0/36 | 5/0 | 4.63 (0.23; 93.20) | 0.05 (-0.03; 0.14) | 19
Lok, 1992 ^93^ Interferon alpha-2b (IntronA; Schering Plough, Kenilworth, NJ), 4/10 MU 3 times per week Prednisone, 45, 30, and 15 mg each for 2 weeks, followed by a 2 week rest, 24 weeks | Placebo for 6 weeks + 2 weeks rest then Interferon alpha 2b, 4 /10 MU 3 times per week, 24 weeks | Complete antiviral response: sustained clearance of serum HBV DNA by direct spot hybridization (lower limit of detection of 10 pg/mL) and clearance of HBeAg and HBsAg | 48/48 | 0/40 2/39 | 0/5 | 0.20 (0.01; 3.94) | -0.05 (-0.13; 0.03) | -19
Perez, 1990^95^ Intron A, Schering-Plough Corporation, 4/10 MU 3 times/week for 16 weeks after 6 weeks of prednisone therapy and 2 weeks without treatment Prednisone, 60mg/day for 2 weeks then 40mg/day for 2 weeks, and then 20mg/day for 2 weeks, 24 weeks | Intron A, Schering-Plough Corporation, 4 /10 MU 3 time/week for 16 weeks after 24 weeks of no treatment, 40 weeks | Normal ALT | 48/64 | 2/17 1/18 | 12/6 | 2.12 (0.21; 21.27) | 0.06 (-0.12; 0.25) | 16
| Intron A, Schering-Plough Corporation, 4 /10 MU 3 time/week for 16 weeks after 24 weeks of no treatment, 40 weeks | Discontinuation due to adverse effects | 22/40 | 0/17 1/18 | 0/6 | 0.35 (0.02; 8.09) | -0.06 (-0.20; 0.09) | -18
| Intron A, Schering-Plough Corporation, 4 /10 MU 3 time/week for 16 weeks after 24 weeks of no treatment, 40 weeks | Reduction in dose due to adverse effects | 22/40 | 2/17 2/18 | 12/11 | 1.06 (0.17; 6.70) | 0.01 (-0.20; 0.22) | 153
| Intron A, Schering-Plough Corporation, 4 /10 MU 3 time/week for 16 weeks after 24 weeks of no treatment, 40 weeks | Elimination of HBeAg | 48/64 | 10/17 7/18 | 59/39 | 1.51 (0.75; 3.05) | 0.20 (-0.13; 0.52) | 5
| Intron A, Schering-Plough Corporation, 4 /10 MU 3 time/week for 16 weeks after 24 weeks of no treatment, 40 weeks | HBeAg seroconversion | 48/64 | 8/17 6/18 | 47/33 | 1.41 (0.62; 3.22) | 0.14 (-0.18; 0.46) | 7
| Intron A, Schering-Plough Corporation, 4 /10 MU 3 time/week for 16 weeks after 24 weeks of no treatment, 40 weeks | Undetectable HBV DNA | 48/64 | 9/17 6/18 | 53/33 | 1.59 (0.72; 3.51) | 0.20 (-0.13; 0.52) | 5
Elimination of HBsAg | 48/64 | 1/17 0/18 | 6/0 | 3.17 (0.14; 72.80) | 0.06 (-0.09; 0.21) | 17
Hadziyannis, 1990^88^ Interferon Alfa 2b, 1/3 MU 3 times per week, 16 weeks | No treatment, 16 weeks | Complete response: loss of HBV DNA and normalization of ALT | 16/16 | 10/25 0/25 | 40/0 | 21.00 (1.30; 340.02) | 0.40 (0.20; 0.60) | 2
Hadziyannis, 1990^88^ Interferon Alfa 2b, 1/3 MU 3 times per week, 16 weeks | No treatment, 16 weeks | Complete response: loss of HBV DNA and normalization of ALT | 40/40 | 8/25 1/25 | 32/4 | 8.00 (1.08; 59.32) | 0.28 (0.08; 0.48) | 4
Hadziyannis, 1990^88^ Interferon Alfa 2b, 1/3 MU 3 times per week, 16 weeks | No treatment, 16 weeks | 64/64 | 11/25 2/25 | 44/8 | 5.50 (1.36; 22.32) | 0.36 (0.14; 0.58) | 3
Hadziyannis, 1990^88^ Interferon Alfa 2b, 1/3 MU 3 times per week, 16 weeks | No treatment, 16 weeks | Partial response: reduction in HBV DNA and ALT by >50 from baseline level | 16/16 | 7/25 4/25 | 28/16 | 1.75 (0.58; 5.24) | 0.12 (-0.11; 0.35) | 8
Hadziyannis, 1990^88^ Interferon Alfa 2b, 1/3 MU 3 times per week, 16 weeks | No treatment, 16 weeks | Partial response: reduction in HBV DNA and ALT by >50 from baseline level | 40/40 | 6/25 5/25 | 24/20 | 1.20 (0.42; 3.43) | 0.04 (-0.19; 0.27) | 25
Hadziyannis, 1990^88^ Interferon Alfa 2b, 1/3 MU 3 times per week, 16 weeks | No treatment, 16 weeks | 64/64 | 3/25 6/25 | 12/24 | 0.50 (0.14; 1.78) | -0.12 (-0.33; 0.09) | -8
Reappearance of HBV DNA and increase in ALT | 112/112 | 4/25 2/25 | 16/8 | 2.00 (0.40; 9.95) | 0.08 (-0.10; 0.26) | 12
Műller, 1990^87^ Recombinant interferon alfa-2b (Intron A, R Schering-Plough, Essex Corporation), 1/3 MU 3 times per week, 16 weeks | No treatment, 16 weeks | Complete response: loss of HBs Ag, HBeAg, and HBV DNA, and normalization of ALT | 40/40 | 1/30 0/28 | 3/0 | 2.81 (0.12; 66.17) | 0.03 (-0.06; 0.12) | 30
Műller, 1990^87^ Recombinant interferon alfa-2b (Intron A, R Schering-Plough, Essex Corporation), 1/3 MU 3 times per week, 16 weeks | No treatment, 16 weeks | Partial response: loss of HBeAg and HBV DNA, and normalization of ALT | 40/40 | 8/30 0/28 | 27/0 | 15.90 (0.96; 263.32) | 0.27 (0.10; 0.43) | 4
Műller, 1990^87^ Recombinant interferon alfa-2b (Intron A, R Schering-Plough, Essex Corporation), 1/3 MU 3 times per week, 16 weeks | No treatment, 16 weeks | Loss HBV DNA and HBeAg seroconversion | 40/40 | 9/30 3/28 | 30/11 | 2.80 (0.84; 9.30) | 0.19 (-0.01; 0.39) | 5
Műller, 1990^87^ Recombinant interferon alfa-2b (Intron A, R Schering-Plough, Essex Corporation), 1/3 MU 3 times per week, 16 weeks | No treatment, 16 weeks | Discontinuation due to overted depression | 16/16 | 1/30 0/28 | 3/0 | 2.81 (0.12; 66.17) | 0.03 (-0.06; 0.12) | 30
Developing of IFN neutralizing antibodies | 16/16 | 2/30 0/28 | 7/0 | 4.68 (0.23; 93.37) | 0.07 (-0.04; 0.17) | 15
Waked, 1990^89^ Intron A, Schering-Plough Inc, USA, 2/5 MU/m2 3 times weekly (n = 12) or daily (n = 8), outcomes reported after both doses together, 16 weeks | No treatment, 16 weeks | Death | 16/16 | 3/20 1/20 | 15/5 | 3.00 (0.34; 26.45) | 0.10 (-0.08; 0.28) | 10
Waked, 1990^89^ Intron A, Schering-Plough Inc, USA, 2/5 MU/m2 3 times weekly (n = 12) or daily (n = 8), outcomes reported after both doses together, 16 weeks | No treatment, 16 weeks | 64/80 | 0/20 2/20 | 0/10 | 0.20 (0.01; 3.92) | -0.10 (-0.25; 0.05) | -10
Waked, 1990^89^ Intron A, Schering-Plough Inc, USA, 2/5 MU/m2 3 times weekly (n = 12) or daily (n = 8), outcomes reported after both doses together, 16 weeks | No treatment, 16 weeks | Incident cirrhosis | 64/80 | 1/20 2/20 | 5/10 | 0.50 (0.05; 5.08) | -0.05 (-0.21; 0.11) | -20
Waked, 1990^89^ Intron A, Schering-Plough Inc, USA, 2/5 MU/m2 3 times weekly (n = 12) or daily (n = 8), outcomes reported after both doses together, 16 weeks | No treatment, 16 weeks | Improved histology | 64/80 | 4/20 1/20 | 20/5 | 4.00 (0.49; 32.72) | 0.15 (-0.05; 0.35) | 7
Waked, 1990^89^ Intron A, Schering-Plough Inc, USA, 2/5 MU/m2 3 times weekly (n = 12) or daily (n = 8), outcomes reported after both doses together, 16 weeks | No treatment, 16 weeks | Loss of HBeAg | 16/16 | 16/20 5/20 | 80/25 | 3.20 (1.45; 7.05) | 0.55 (0.29; 0.81) | 2
Waked, 1990^89^ Intron A, Schering-Plough Inc, USA, 2/5 MU/m2 3 times weekly (n = 12) or daily (n = 8), outcomes reported after both doses together, 16 weeks | No treatment, 16 weeks | HBeAg seroconversion | 16/16 | 11/20 4/20 | 55/20 | 2.75 (1.05; 7.20) | 0.35 (0.07; 0.63) | 3
Waked, 1990^89^ Intron A, Schering-Plough Inc, USA, 2/5 MU/m2 3 times weekly (n = 12) or daily (n = 8), outcomes reported after both doses together, 16 weeks | No treatment, 16 weeks | Loss of HBsAg | 16/16 | 5/20 3/20 | 25/15 | 1.67 (0.46; 6.06) | 0.10 (-0.15; 0.35) | 10
Waked, 1990^89^ Intron A, Schering-Plough Inc, USA, 2/5 MU/m2 3 times weekly (n = 12) or daily (n = 8), outcomes reported after both doses together, 16 weeks | No treatment, 16 weeks | HBsAg seroconversion | 16/16 | 4/20 1/20 | 20/5 | 4.00 (0.49; 32.72) | 0.15 (-0.05; 0.35) | 7
Waked, 1990^89^ Intron A, Schering-Plough Inc, USA, 2/5 MU/m2 3 times weekly (n = 12) or daily (n = 8), outcomes reported after both doses together, 16 weeks | No treatment, 16 weeks | Loss of HBeAg | 64/80 | 13/20 5/20 | 65/25 | 2.60 (1.14; 5.93) | 0.40 (0.12; 0.68) | 2
Waked, 1990^89^ Intron A, Schering-Plough Inc, USA, 2/5 MU/m2 3 times weekly (n = 12) or daily (n = 8), outcomes reported after both doses together, 16 weeks | No treatment, 16 weeks | HBeAg seroconversion | 64/80 | 10/20 5/20 | 50/25 | 2.00 (0.83; 4.81) | 0.25 (-0.04; 0.54) | 4
Waked, 1990^89^ Intron A, Schering-Plough Inc, USA, 2/5 MU/m2 3 times weekly (n = 12) or daily (n = 8), outcomes reported after both doses together, 16 weeks | No treatment, 16 weeks | Loss of HBsAg | 64/80 | 6/20 3/20 | 30/15 | 2.00 (0.58; 6.91) | 0.15 (-0.10; 0.40) | 7
HBsAg seroconversion | 64/80 | 4/20 1/20 | 20/5 | 4.00 (0.49; 32.72) | 0.15 (-0.05; 0.35) | 7
Perrillo, 1990^96^ Interferon Alfa 2b (Intron-A, Schering-Plough), 5 MU daily Prednisone, decreasing daily doses of 60, 40, and 20mg each for 2 weeks followed by 2 weeks rest, 24 weeks | Placebo oral for 6 weeks followed by 2 weeks rest then Intron-A 5 MU daily, 24 weeks | Normalization of ALT and AST | 48/48 | 19/44 18/41 | 43/44 | 0.98 (0.61; 1.60) | -0.01 (-0.22; 0.20) | -139
Perrillo, 1990^96^ Interferon Alfa 2b (Intron-A, Schering-Plough), 5 MU daily Prednisone, decreasing daily doses of 60, 40, and 20mg each for 2 weeks followed by 2 weeks rest, 24 weeks | Placebo orally for 6 weeks followed by 2 weeks rest then Intron-A 1 MU daily, 24 weeks | Normalization of ALT and AST | 48/48 | 19/44 11/41 | 43/27 | 1.61 (0.88; 2.96) | 0.16 (-0.04; 0.36) | 6
No treatment, 24 weeks | Normalization of ALT and AST | 48/48 | 19/44 8/43 | 43/19 | 2.32 (1.14; 4.73) | 0.25 (0.06; 0.43) | 4
Perrillo, 1990^96^ Interferon Alfa 2b (Intron-A, Schering-Plough), 5 MU daily placebo orally for 6 weeks followed by 2 weeks rest then Intron-A 5 MU daily, 24 weeks | Placebo orally for 6 weeks followed by 2 weeks rest then Intron-A 1 MU daily, 24 weeks | Normalization of ALT and AST | 48/48 | 18/41 11/41 | 44/27 | 1.64 (0.89; 3.02) | 0.17 (-0.03; 0.37) | 6
Perrillo, 1990^96^ Interferon Alfa 2b (Intron-A, Schering-Plough), 5 MU daily placebo orally for 6 weeks followed by 2 weeks rest then Intron-A 5 MU daily, 24 weeks | No treatment, 24 weeks | Normalization of ALT and AST | 48/48 | 18/41 8/43 | 44/19 | 2.36 (1.15; 4.82) | 0.25 (0.06; 0.44) | 4
11/41 8/43 | 27/19 | 1.44 (0.65; 3.22) | 0.08 (-0.10; 0.26) | 12
Perrillo, 1990^96^ Interferon Alfa 2b (Intron-A, Schering-Plough), 5 MU daily Prednisone, decreasing daily doses of 60, 40, and 20mg each for 2 weeks followed by 2 weeks rest, 24 weeks | Placebo orally for 6 weeks followed by 2 weeks rest then Intron-A 5 MU daily, 24 weeks | Loss of HBV DNA and HBeAg | 24/24 | 16/44 15/41 | 36/37 | 0.99 (0.57; 1.74) | 0.00 (-0.21; 0.20) | -451
Perrillo, 1990^96^ Interferon Alfa 2b (Intron-A, Schering-Plough), 5 MU daily Prednisone, decreasing daily doses of 60, 40, and 20mg each for 2 weeks followed by 2 weeks rest, 24 weeks | Placebo oral for 6 weeks followed by 2 weeks rest than Intron-A 1 MU daily, 24 weeks | Loss of HBV DNA and HBeAg | 24/24 | 16/44 7/41 | 36/17 | 2.13 (0.98; 4.64) | 0.19 (0.01; 0.38) | 5
No treatment, 24 weeks | Loss of HBV DNA and HBeAg | 24/24 | 16/44 3/43 | 36/7 | 5.21 (1.64; 16.61) | 0.29 (0.13; 0.46) | 3
Perrillo, 1990^96^ Interferon Alfa 2b (Intron-A, Schering-Plough), placebo orally for 6 weeks followed by 2 weeks rest then Intron-A 5 MU daily, 24 weeks | Placebo orally for 6 weeks followed by 2 weeks rest then Intron-A 1 MU daily, 24 weeks | Loss of HBV DNA and HBeAg | 24/24 | 15/41 7/41 | 37/17 | 2.14 (0.98; 4.70) | 0.20 (0.01; 0.38) | 5
Perrillo, 1990^96^ Interferon Alfa 2b (Intron-A, Schering-Plough), placebo orally for 6 weeks followed by 2 weeks rest then Intron-A 5 MU daily, 24 weeks | No treatment, 24 weeks | Loss of HBV DNA and HBeAg | 24/24 | 15/41 3/43 | 37/7 | 5.24 (1.64; 16.79) | 0.30 (0.13; 0.46) | 3
7/41 3/43 | 17/7 | 2.45 (0.68; 8.83) | 0.10 (-0.04; 0.24) | 10
Perrillo 1990 2195346 Interferon Alfa 2b (Intron-A, Schering-Plough), 5 MU daily Prednisone, decreasing daily doses of 60, 40, and 20mg each for 2 weeks followed by 2 weeks rest, 24 weeks | Placebo orally for 6 weeks followed by 2 weeks rest then Intron-A 5 MU daily, 24 weeks | Loss of HBV DNA | 48/48 | 4/44 3/41 | 9/7 | 1.24 (0.30; 5.22) | 0.02 (-0.10; 0.13) | 56
Perrillo, 1990^96^ Interferon Alfa 2b (Intron-A, Schering-Plough), 5 MU daily Prednisone, 40 decreasing daily doses of 60, 40, and 20mg each for 2 weeks followed by 2 weeks rest, 24 weeks | Interferon Alfa 2b (placebo orally for 6 weeks followed by 2 weeks rest then Intron-A 1 MU daily, 24 weeks | Loss of HBV DNA | 48/48 | 4/44 4/41 | 9/10 | 0.93 (0.25; 3.48) | -0.01 (-0.13; 0.12) | -150
No treatment, 24 weeks | Loss of HBV DNA | 48/48 | 4/44 2/43 | 9/5 | 1.95 (0.38; 10.12) | 0.04 (-0.06; 0.15) | 23
Perrillo, 1990^96^ Interferon Alfa 2b (Intron-A, Schering-Plough), placebo orally for 6 weeks followed by 2 weeks rest then Intron-A 5 MU daily, 24 weeks | Placebo orally for 6 weeks followed by 2 weeks rest then Intron-A 1 MU daily, 24 weeks | Loss of HBV DNA | 48/48 | 3/41 4/41 | 7/10 | 0.75 (0.18; 3.14) | -0.02 (-0.15; 0.10) | -41
Perrillo, 1990^96^ Interferon Alfa 2b (Intron-A, Schering-Plough), placebo orally for 6 weeks followed by 2 weeks rest then Intron-A 5 MU daily, 24 weeks | No treatment, 24 weeks | Loss of HBV DNA | 48/48 | 3/41 2/43 | 7/5 | 1.57 (0.28; 8.94) | 0.03 (-0.07; 0.13) | 38
4/41 2/43 | 10/5 | 2.10 (0.41; 10.84) | 0.05 (-0.06; 0.16) | 20
Perrillo, 1990^96^ Interferon Alfa 2b (Intron-A, Schering-Plough), 5 MU daily Prednisone, decreasing daily doses of 60, 40, and 20mg each for 2 weeks followed by 2 weeks rest, 24 weeks | Placebo oral for 6 weeks followed by 2 weeks rest than Intron-A 5 MU daily, 24 weeks | Loss of HBsAg | 24/24 | 5/44 5/41 | 11/12 | 0.93 (0.29; 2.99) | -0.01 (-0.15; 0.13) | -120
Perrillo, 1990^96^ Interferon Alfa 2b (Intron-A, Schering-Plough), 5 MU daily Prednisone, decreasing daily doses of 60, 40, and 20mg each for 2 weeks followed by 2 weeks rest, 24 weeks | Placebo oral for 6 weeks followed by 2 weeks rest than Intron-A 1 MU daily, 24 weeks | Loss of HBsAg | 24/24 | 5/44 1/41 | 11/2 | 4.66 (0.57; 38.22) | 0.09 (-0.02; 0.19) | 11
No treatment, 24 weeks | Loss of HBsAg | 24/24 | 5/44 0/43 | 11/0 | 10.76 (0.61; 188.77) | 0.11 (0.01; 0.21) | 9
Perrillo, 1990^96^ Interferon Alfa 2b (Intron-A, Schering-Plough), placebo orally for 6 weeks followed by 2 weeks rest then Intron-A 5 MU daily, 24 weeks | Placeboorally for 6 weeks followed by 2 weeks rest then Intron-A 1 MU daily, 24 weeks | Loss of HBsAg | 24/24 | 5/41 1/41 | 12/2 | 5.00 (0.61; 40.95) | 0.10 (-0.01; 0.21) | 10
Perrillo, 1990^96^ Interferon Alfa 2b (Intron-A, Schering-Plough), placebo orally for 6 weeks followed by 2 weeks rest then Intron-A 5 MU daily, 24 weeks | No treatment, 24 weeks | Loss of HBsAg | 24/24 | 5/41 0/43 | 12/0 | 11.52 (0.66; 202.03) | 0.12 (0.02; 0.23) | 8
1/41 0/43 | 2/0 | 3.14 (0.13; 75.02) | 0.02 (-0.04; 0.09) | 41
Perrillo, 1990^96^ Interferon Alfa 2b (Intron-A, Schering-Plough), 5 MU daily Prednisone, decreasing daily doses of 60,40, and 20mg each for 2 weeks followed by 2 weeks rest, 24 weeks | Placebo orally for 6 weeks followed by 2 weeks rest then Intron-A 5 MU daily, 24 weeks | Reactivation of HBeAg or reappearance of HBV DNA | 48/48 | 1/44 0/41 | 2/0 | 2.80 (0.12; 66.85) | 0.02 (-0.04; 0.08) | 44
Perrillo, 1990^96^ Interferon Alfa 2b (Intron-A, Schering-Plough), 5 MU daily Prednisone, decreasing daily doses of 60,40, and 20mg each for 2 weeks followed by 2 weeks rest, 24 weeks | Placebo orally for 6 weeks followed by 2 weeks rest then Intron-A 1 MU daily, 24 weeks | Reactivation of HBeAg or reappearance of HBV DNA | 48/48 | 1/44 1/41 | 2/2 | 0.93 (0.06; 14.42) | 0.00 (-0.07; 0.06) | -601
No treatment, 24 weeks | Reactivation of HBeAg or reappearance of HBV DNA | 48/48 | 1/44 0/43 | 2/0 | 2.93 (0.12; 70.08) | 0.02 (-0.04; 0.08) | 44
Perrillo, 1990^96^ Interferon Alfa 2b (Intron-A, Schering-Plough), placebo orally for 6 weeks followed by 2 weeks rest then Intron-A 5 MU daily, 24 weeks | Placebo orally for 6 weeks followed by 2 weeks rest then Intron-A 1 MU daily, 24 weeks | Reactivation of HBeAg or reappearance of HBV DNA | 48/48 | 0/41 1/41 | 0/2 | 0.33 (0.01; 7.95) | -0.02 (-0.09; 0.04) | -41
Perrillo, 1990^96^ Interferon Alfa 2b (Intron-A, Schering-Plough), placebo orally for 6 weeks followed by 2 weeks rest then Intron-A 5 MU daily, 24 weeks | No treatment, 24 weeks | Reactivation of HBeAg or reappearance of HBV DNA | 48/48 | 0/41 0/43 | | | 0.00 (-0.05; 0.05)
2/0 | 3.14 (0.13; 75.02) | 0.02 (-0.04; 0.09) | 41
Zarski, 1994^91^ interferon alpha-2b (Intron A, Schering-Plough Corporation), 2 /5 MU 3 times a week Prednisone, decreasing doses of 60, 40, 20 mg for 6 weeks, 24 weeks | Interferon alpha-2b (Intron A, Schering-Plough Corporation), 2/5 MU 3 times per week, 24 weeks | Chronic active hepatitis | 48/48 | 18/31 15/25 | 58/60 | 0.97 (0.62; 1.50) | -0.02 (-0.28; 0.24) | -52
Zarski, 1994^91^ interferon alpha-2b (Intron A, Schering-Plough Corporation), 2 /5 MU 3 times a week Prednisone, decreasing doses of 60, 40, 20 mg for 6 weeks, 24 weeks | Interferon alpha-2b (Intron A, Schering-Plough Corporation), 2/5 MU 3 times per week, 24 weeks | Cirrhosis | 48/48 | 3/31 4/25 | 10/16 | 0.60 (0.15; 2.46) | -0.06 (-0.24; 0.11) | -16
Zarski, 1994^91^ interferon alpha-2b (Intron A, Schering-Plough Corporation), 2 /5 MU 3 times a week Prednisone, decreasing doses of 60, 40, 20 mg for 6 weeks, 24 weeks | Interferon alpha-2b (Intron A, Schering-Plough Corporation), 2/5 MU 3 times per week, 24 weeks | Sustained clearance of HBV DNA during therapy + HBeAg seroconversion during or after therapy | 48/48 | 7/31 10/25 | 23/40 | 0.56 (0.25; 1.27) | -0.17 (-0.42; 0.07) | -6
Zarski, 1994^91^ interferon alpha-2b (Intron A, Schering-Plough Corporation), 2 /5 MU 3 times a week Prednisone, decreasing doses of 60, 40, 20 mg for 6 weeks, 24 weeks | Interferon alpha-2b (Intron A, Schering-Plough Corporation), 2/5 MU 3 times per week, 24 weeks | Sustained clearance of HBV DNA during therapy | 48/48 | 4/31 2/25 | 13/8 | 1.61 (0.32; 8.10) | 0.05 (-0.11; 0.21) | 20
Zarski, 1994^91^ interferon alpha-2b (Intron A, Schering-Plough Corporation), 2 /5 MU 3 times a week Prednisone, decreasing doses of 60, 40, 20 mg for 6 weeks, 24 weeks | Interferon alpha-2b (Intron A, Schering-Plough Corporation), 2/5 MU 3 times per week, 24 weeks | HBsAg loss | 48/48 | 5/31 1/25 | 16/4 | 4.03 (0.50; 32.32) | 0.12 (-0.03; 0.27) | 8
Transient clearance of HBV DNA and HBeAg during therapy but reappearance by the end of the study | 48/48 | 5/31 6/25 | 16/24 | 0.67 (0.23; 1.95) | -0.08 (-0.29; 0.13) | -13
Reichen, 1994^90^ Recombinant interferon alpha 2b (Intron), 1.5 MU three times per week Prednisone, 50mg for 2 weeks, 25 mg for 2 weeks, then 2 week drug free interval, 24 weeks | Recombinant interferon alpha 2b (Intron), placebo withdrawal followed 5 MU 3 times per week, 24 weeks | Death from hepatorenal syndrome | 24/24 | 0/18 2/19 | 0/11 | 0.21 (0.01; 4.11) | -0.11 (-0.27; 0.06) | -9
Reichen, 1994^90^ Recombinant interferon alpha 2b (Intron), placebo withdrawal followed by 1.5 MU 3 times per week, 24 weeks | Recombinant interferon alpha 2b (Intron), placebo withdrawal followed 5 MU 3 times per week, 24 weeks | Death from hepatorenal syndrome | 48/48 | 0/19 2/19 | 0/11 | 0.20 (0.01; 3.91) | -0.11 (-0.27; 0.06) | -9
Reichen, 1994^90^ Recombinant interferon alpha 2b (Intron), 1.5 MU 3 times per week Prednisone, 50mg for 2 weeks, 25 mg for two weeks, then 2 week drug free interval, 24 weeks | Recombinant interferon alpha 2b (Intron), placebo withdrawal followed by 1.5 MU 3 times per week, 24 weeks | Loss of HBeAg | 24/24 | 11/18 16/19 | 61/84 | 0.73 (0.48; 1.10) | -0.23 (-0.51; 0.05) | -4
Recombinant interferon alpha 2b (Intron), placebo withdrawal followed by 5 MU 3 times per week, 24 weeks | Loss of HBeAg | 24/24 | 11/18 7/19 | 61/37 | 1.66 (0.83; 3.32) | 0.24 (-0.07; 0.56) | 4
Reichen, 1994^90^ Recombinant interferon alpha 2b (Intron), placebo withdrawal followed 1.5 MU 3 times per week, 24 weeks | Recombinant interferon alpha 2b (Intron), placebo withdrawal followed 5 MU 3 times per week, 24 weeks | Loss of HBeAg | 24/24 | 16/19 7/19 | 84/37 | 2.29 (1.23; 4.25) | 0.47 (0.20; 0.75) | 2
Reichen, 1994^90^ Recombinant interferon alpha 2b (Intron), 1.5 MU three times per week Prednisone, 50mg for 2 weeks, 25 mg for two weeks, then 2 week drug free interval, 24 weeks | Recombinant interferon alpha 2b (Intron), placebo withdrawal followed by 1.5 MU 3 times per week, 24 weeks | Loss of HBeAg | 48/48 | 10/18 12/19 | 56/63 | 0.88 (0.51; 1.51) | -0.08 (-0.39; 0.24) | -13
Recombinant interferon alpha 2b (Intron), placebo withdrawal followed by 5 MU 3 times per week, 24 weeks | Loss of HBeAg | 48/48 | 10/18 13/19 | 56/68 | 0.81 (0.49; 1.36) | -0.13 (-0.44; 0.18) | -8
Reichen, 1994^90^ Recombinant interferon alpha 2b (Intron), placebo withdrawal followed by 1.5 MU 3 times per week, 24 weeks | Recombinant interferon alpha 2b (Intron), placebo withdrawal followed by 5 MU 3 times per week, 24 weeks | Loss of HBeAg | 48/48 | 12/19 13/19 | 63/68 | 0.92 (0.58; 1.46) | -0.05 (-0.35; 0.25) | -19
Reichen, 1994^90^ Recombinant interferon alpha 2b (Intron), 1.5 MU three times per week Prednisone, 50mg for 2 weeks, 25 mg for 2 weeks, then 2 week drug free interval, 24 weeks | Recombinant interferon alpha 2b (Intron), placebo withdrawal followed by 1.5 MU 3 times per week, 24 weeks | Loss of HBeAg | 96/96 | 5/18 9/19 | 28/47 | 0.59 (0.24; 1.42) | -0.20 (-0.50; 0.11) | -5
Recombinant interferon alpha 2b (Intron), placebo withdrawal followed by 5 MU 3 times per week, 24 weeks | Loss of HBeAg | 96/96 | 5/18 11/19 | 28/58 | 0.48 (0.21; 1.11) | -0.30 (-0.60; 0.00) | -3
Reichen, 1994^90^ Recombinant interferon alpha 2b (Intron), placebo withdrawal followed by 1.5 MU 3 times per week, 24 weeks | Recombinant interferon alpha 2b (Intron), placebo withdrawal followed by 5 MU 3 times per week, 24 weeks | Loss of HBeAg | 96/96 | 9/19 11/19 | 47/58 | 0.82 (0.44; 1.51) | -0.11 (-0.42; 0.21) | -9
Reichen, 1994^90^ Recombinant interferon alpha 2b (Intron), 1.5 MU 3 times per week Prednisone, 50mg for 2 weeks, 25 mg for 2 weeks, then 2 week drug free interval, 24 weeks | Recombinant interferon alpha 2b (Intron), placebo withdrawal followed by 1.5 MU three times per week, 24 weeks | Loss of HBV DNA | 24/24 | 10/18 11/19 | 56/58 | 0.96 (0.55; 1.69) | -0.02 (-0.34; 0.30) | -43
Recombinant interferon alpha 2b (Intron), placebo withdrawal followed by 5 MU 3 times per week, 24 weeks | Loss of HBV DNA | 24/24 | 10/18 10/19 | 56/53 | 1.06 (0.58; 1.91) | 0.03 (-0.29; 0.35) | 34
Reichen, 1994^90^ Recombinant interferon alpha 2b (Intron), placebo withdrawal followed by 1.5 MU 3 times per week, 24 weeks | Recombinant interferon alpha 2b (Intron), placebo withdrawal followed by 5 MU 3 times per week, 24 weeks | Loss of HBV DNA | 24/24 | 11/19 10/19 | 58/53 | 1.10 (0.62; 1.95) | 0.05 (-0.26; 0.37) | 19
Reichen, 1994^90^ Recombinant interferon alpha 2b (Intron), 1.5 MU 3 times per week Prednisone, 50mg for 2 weeks, 25 mg for 2 weeks, then 2 week drug free interval, 24 weeks | Recombinant interferon alpha 2b (Intron), placebo withdrawal followed by 1.5 MU 3 times per week, 24 weeks | Loss of HBV DNA | 48/48 | 10/18 13/19 | 56/68 | 0.81 (0.49; 1.36) | -0.13 (-0.44; 0.18) | -8
Recombinant interferon alpha 2b (Intron), placebo withdrawal followed by 5 MU 3 times per week, 24 weeks | Loss of HBV DNA | 48/48 | 10/18 11/19 | 56/58 | 0.96 (0.55; 1.69) | -0.02 (-0.34; 0.30) | -43
Reichen, 1994^90^ Recombinant interferon alpha 2b (Intron), placebo withdrawal followed by 1.5 MU 3 times per week, 24 weeks | Recombinant interferon alpha 2b (Intron), placebo withdrawal followed by 5 MU 3 times per week, 24 weeks | Loss of HBV DNA | 48/48 | 13/19 11/19 | 68/58 | 1.18 (0.72; 1.93) | 0.11 (-0.20; 0.41) | 9
Reichen, 1994^90^ Recombinant interferon alpha 2b (Intron), 1.5 MU 3 times per week Prednisone, 50mg for 2 weeks, 25 mg for two weeks, then 2 week drug free interval, 24 weeks | Recombinant interferon alpha 2b (Intron), placebo withdrawal followed by 1.5 MU 3 times per week, 24 weeks | Loss of HBV DNA | 96/96 | 5/18 10/19 | 28/53 | 0.53 (0.22; 1.25) | -0.25 (-0.55; 0.06) | -4
Recombinant interferon alpha 2b (Intron), placebo withdrawal followed by 5 MU 3 times per week, 24 weeks | Loss of HBV DNA | 96/96 | 5/18 6/19 | 28/32 | 0.88 (0.32; 2.38) | -0.04 (-0.33; 0.26) | -26
Reichen, 1994^90^ Recombinant interferon alpha 2b (Intron), placebo withdrawal followed by 1.5 MU 3 times per week, 24 weeks | Recombinant interferon alpha 2b (Intron), placebo withdrawal followed by 5 MU 3 times per week, 24 weeks | Loss of HBV DNA | 96/96 | 10/19 6/19 | 53/32 | 1.67 (0.76; 3.66) | 0.21 (-0.10; 0.52) | 5
Di Bisceglie, 1993^86^ “IFN-a2b (Intron A, Schering-Plough, NJ)”, 4 /10 MU 3 times per week, 16 weeks | No treatment, 16 weeks | Normalization of ALT | 24/24 | 9/25 0/22 | 36/0 | 16.81 (1.03; 73.08) | 0.36 (0.17; 0.55) | 3
Di Bisceglie, 1993^86^ “IFN-a2b (Intron A, Schering-Plough, NJ)”, 4 /10 MU 3 times per week, 16 weeks | No treatment, 16 weeks | Discontinuation of therapy due to adverse effects | 39794 | 3/25 0/22 | 12/0 | 6.19 (0.34; 113.62) | 0.12 (-0.02; 0.26) | 8
Di Bisceglie, 1993^86^ “IFN-a2b (Intron A, Schering-Plough, NJ)”, 4 /10 MU 3 times per week, 16 weeks | No treatment, 16 weeks | Reduction in dose due to adverse effects | 39794 | 16/25 0/22 | 64/0 | 29.19 (1.85; 59.85) | 0.64 (0.45; 0.83) | 2
Di Bisceglie, 1993^86^ “IFN-a2b (Intron A, Schering-Plough, NJ)”, 4 /10 MU 3 times per week, 16 weeks | No treatment, 16 weeks | Fatigue | 39794 | 12/25 0/22 | 48/0 | 22.12 (1.39; 53.09) | 0.48 (0.28; 0.68) | 2
Di Bisceglie, 1993^86^ “IFN-a2b (Intron A, Schering-Plough, NJ)”, 4 /10 MU 3 times per week, 16 weeks | No treatment, 16 weeks | Marrow suppression | 39794 | 2/25 0/22 | 8/0 | 4.42 (0.22; 87.44) | 0.08 (-0.05; 0.21) | 12
Di Bisceglie, 1993^86^ “IFN-a2b (Intron A, Schering-Plough, NJ)”, 4 /10 MU 3 times per week, 16 weeks | No treatment, 16 weeks | Nausea | 39794 | 3/25 0/22 | 12/0 | 6.19 (0.34; 113.62) | 0.12 (-0.02; 0.26) | 8
Di Bisceglie, 1993^86^ “IFN-a2b (Intron A, Schering-Plough, NJ)”, 4 /10 MU 3 times per week, 16 weeks | No treatment, 16 weeks | Infections | 39794 | 2/25 0/22 | 8/0 | 4.42 (0.22; 87.44) | 0.08 (-0.05; 0.21) | 12
Di Bisceglie, 1993^86^ “IFN-a2b (Intron A, Schering-Plough, NJ)”, 4 /10 MU 3 times per week, 16 weeks | No treatment, 16 weeks | Arthralgia | 39794 | 2/25 0/22 | 8/0 | 4.42 (0.22; 87.44) | 0.08 (-0.05; 0.21) | 12
Di Bisceglie, 1993^86^ “IFN-a2b (Intron A, Schering-Plough, NJ)”, 4 /10 MU 3 times per week, 16 weeks | No treatment, 16 weeks | Jaundice | 39794 | 1/25 0/22 | 4/0 | 2.65 (0.11; 62.00) | 0.04 (-0.07; 0.15) | 25
Di Bisceglie, 1993^86^ “IFN-a2b (Intron A, Schering-Plough, NJ)”, 4 /10 MU 3 times per week, 16 weeks | No treatment, 16 weeks | Depression | 39794 | 1/25 0/22 | 4/0 | 2.65 (0.11; 62.00) | 0.04 (-0.07; 0.15) | 25
Di Bisceglie, 1993^86^ “IFN-a2b (Intron A, Schering-Plough, NJ)”, 4 /10 MU 3 times per week, 16 weeks | No treatment, 16 weeks | HBV DNA and HBeAg negative | 24/24 | 11/25 1/22 | 44/5 | 9.68 (1.36; 69.09) | 0.39 (0.18; 0.61) | 3
Di Bisceglie, 1993^86^ “IFN-a2b (Intron A, Schering-Plough, NJ)”, 4 /10 MU 3 times per week, 16 weeks | No treatment, 16 weeks | Loss of HBsAg | 24/24 | 4/25 0/22 | 16/0 | 7.96 (0.45; 140.05) | 0.16 (0.00; 0.32) | 6
Di Bisceglie, 1993^86^ “IFN-a2b (Intron A, Schering-Plough, NJ)”, 4 /10 MU 3 times per week, 16 weeks | No treatment, 16 weeks | HBV DNA undetectable | 24/24 | 13/25 1/22 | 52/5 | 11.44 (1.63; 80.54) | 0.47 (0.26; 0.69) | 2
Loss of HBeAg | 24/24 | 11/25 1/22 | 44/5 | 9.68 (1.36; 69.09) | 0.39 (0.18; 0.61) | 3
Perez, 1993^92^ Interferon alfa-2b (INTRON A, Schering-Plough Corporation), 4 /10 MU 3 times weekly Prednisone, pretreatment with 60, 40, 20 mg daily every 2 weeks, followed by 2 week free drug period, 24 weeks | Interferon alfa-2b (INTRON A, Schering-Plough Corporation), 4/10 MU 3 times per week, 16 weeks | ALT normalization | 48/40 | 16/26 14/24 | 62/58 | 1.05 (0.67; 1.66) | 0.03 (-0.24; 0.30) | 31
| Interferon alfa-2b (INTRON A, Schering-Plough Corporation), 4/10 MU 3 times per week, 16 weeks | Reduction in dose because of severe side effects | 48/40 | 2/26 2/24 | 8/8 | 0.92 (0.14; 6.05) | -0.01 (-0.16; 0.14) | -156
| Interferon alfa-2b (INTRON A, Schering-Plough Corporation), 4/10 MU 3 times per week, 16 weeks | HBeAg loss | 48/40 | 16/26 14/24 | 62/58 | 1.05 (0.67; 1.66) | 0.03 (-0.24; 0.30) | 31
| Interferon alfa-2b (INTRON A, Schering-Plough Corporation), 4/10 MU 3 times per week, 16 weeks | Undetectable HBV DNA | 48/40 | 16/26 14/24 | 62/58 | 1.05 (0.67; 1.66) | 0.03 (-0.24; 0.30) | 31
| Interferon alfa-2b (INTRON A, Schering-Plough Corporation), 4/10 MU 3 times per week, 16 weeks | HBsAg loss | 48/40 | 14/26 11/24 | 54/46 | 1.17 (0.67; 2.06) | 0.08 (-0.20; 0.36) | 12
HBeAg seroconversion | 48/40 | 14/26 11/24 | 54/46 | 1.17 (0.67; 2.06) | 0.08 (-0.20; 0.36) | 12
Műller, 1993^105^ Interferon alfa-2b, 1/3 MU 3 times per week, 16 weeks | No treatment, 16 weeks | Complete response: elimination of HBsAg, HBeAg and HBV-DNA and normal ALT | 40/40 | 1/30 0/28 | 3/0 | 2.81 (0.12; 66.17) | 0.03 (-0.06; 0.12) | 30
Műller, 1993^105^ Interferon alfa-2b, 1/3 MU 3 times per week, 16 weeks | No treatment, 16 weeks | Partial response: elimination of HBeAg and HBV-DNA, while HBsAg persisted, and normal ALT | 40/40 | 8/30 3/28 | 27/11 | 2.49 (0.73; 8.45) | 0.16 (-0.04; 0.35) | 6
Discontinuation due to psychosis | 16/16 | 1/30 0/28 | 3/0 | 2.81 (0.12; 66.17) | 0.03 (-0.06; 0.12) | 30
Lopez-Alcorocho, 1997^85^ Intron A, Schering-Plough Inc, USA, 6/10 MU 3 times per week for 2 months, 5 MU 3 times per week for 2 months and then 3 MU 2 times per week for 2 months, 24 weeks | Intron A, Schering-Plough Inc, USA, 2/10 MU 3 times per week for 2 months, 5 MU 3 times per week for 2 months and then 3 MU 3 times per week for 8 months, 48 weeks | ALT normalization | 18/18 | 4/19 2/19 | 21/11 | 2.00 (0.41; 9.65) | 0.11 (-0.12; 0.33) | 9
Lopez-Alcorocho, 1997^85^ Intron A, Schering-Plough Inc, USA, 6/10 MU 3 times per week for 2 months, 5 MU 3 times per week for 2 months and then 3 MU 2 times per week for 2 months, 24 weeks | Intron A, Schering-Plough Inc, USA, 2/10 MU 3 times per week for 2 months, 5 MU 3 times per week for 2 months and then 3 MU 3 times per week for 8 months, 48 weeks | ALT normalization | 24/24 | 3/19 10/19 | 16/53 | 0.30 (0.10; 0.92) | -0.37 (-0.65; -0.09) | -3
Lopez-Alcorocho, 1997^85^ Intron A, Schering-Plough Inc, USA, 6/10 MU 3 times per week for 2 months, 5 MU 3 times per week for 2 months and then 3 MU 2 times per week for 2 months, 24 weeks | Intron A, Schering-Plough Inc, USA, 2/10 MU 3 times per week for 2 months, 5 MU 3 times per week for 2 months and then 3 MU 3 times per week for 8 months, 48 weeks | ALT normalization | 24/48 | 10/19 5/19 | 53/26 | 2.00 (0.84; 4.75) | 0.26 (-0.04; 0.56) | 4
Lopez-Alcorocho, 1997^85^ Intron A, Schering-Plough Inc, USA, 6/10 MU 3 times per week for 2 months, 5 MU 3 times per week for 2 months and then 3 MU 2 times per week for 2 months, 24 weeks | Intron A, Schering-Plough Inc, USA, 2/10 MU 3 times per week for 2 months, 5 MU 3 times per week for 2 months and then 3 MU 3 times per week for 8 months, 48 weeks | 72/96 | 9/19 8/19 | 47/42 | 1.13 (0.55; 2.29) | 0.05 (-0.26; 0.37) | 19
Lopez-Alcorocho, 1997^85^ Intron A, Schering-Plough Inc, USA, 6/10 MU 3 times per week for 2 months, 5 MU 3 times per week for 2 months and then 3 MU 2 times per week for 2 months, 24 weeks | Intron A, Schering-Plough Inc, USA, 2/10 MU 3 times per week for 2 months, 5 MU 3 times per week for 2 months and then 3 MU 3 times per week for 8 months, 48 weeks | Abnormal ALT, >45IU/L | 72/96 | 3/19 3/19 | 16/16 | 1.00 (0.23; 4.34) | 0.00 (-0.23; 0.23)
Lopez-Alcorocho, 1997^85^ Intron A, Schering-Plough Inc, USA, 6/10 MU 3 times per week for 2 months, 5 MU 3 times per week for 2 months and then 3 MU 2 times per week for 2 months, 24 weeks | Intron A, Schering-Plough Inc, USA, 2/10 MU 3 times per week for 2 months, 5 MU 3 times per week for 2 months and then 3 MU 3 times per week for 8 months, 48 weeks | Death not related to IFN therapy | 24/48 | 0/19 1/19 | 0/5 | 0.33 (0.01; 7.70) | -0.05 (-0.19; 0.08) | -19
Lopez-Alcorocho, 1997^85^ Intron A, Schering-Plough Inc, USA, 6/10 MU 3 times per week for 2 months, 5 MU 3 times per week for 2 months and then 3 MU 2 times per week for 2 months, 24 weeks | Intron A, Schering-Plough Inc, USA, 2/10 MU 3 times per week for 2 months, 5 MU 3 times per week for 2 months and then 3 MU 3 times per week for 8 months, 48 weeks | Loss HBV DNA and ALT normalization | 48/72 | 0/19 4/19 | 0/21 | 0.11 (0.01; 1.93) | -0.21 (-0.41; -0.02) | -5
Lopez-Alcorocho, 1997^85^ Intron A, Schering-Plough Inc, USA, 6/10 MU 3 times per week for 2 months, 5 MU 3 times per week for 2 months and then 3 MU 2 times per week for 2 months, 24 weeks | Intron A, Schering-Plough Inc, USA, 2/10 MU 3 times per week for 2 months, 5 MU 3 times per week for 2 months and then 3 MU 3 times per week for 8 months, 48 weeks | Loss HBV DNA and ALT normalization | 72/96 | 2/19 4/19 | 11/21 | 0.50 (0.10; 2.41) | -0.11 (-0.33; 0.12) | -9
Lopez-Alcorocho, 1997^85^ Intron A, Schering-Plough Inc, USA, 6/10 MU 3 times per week for 2 months, 5 MU 3 times per week for 2 months and then 3 MU 2 times per week for 2 months, 24 weeks | Intron A, Schering-Plough Inc, USA, 2/10 MU 3 times per week for 2 months, 5 MU 3 times per week for 2 months and then 3 MU 3 times per week for 8 months, 48 weeks | Discontinuation due to neuropsychiatric disorder | 24/48 | 0/19 1/19 | 0/5 | 0.33 (0.01; 7.70) | -0.05 (-0.19; 0.08) | -19
Lopez-Alcorocho, 1997^85^ Intron A, Schering-Plough Inc, USA, 6/10 MU 3 times per week for 2 months, 5 MU 3 times per week for 2 months and then 3 MU 2 times per week for 2 months, 24 weeks | Intron A, Schering-Plough Inc, USA, 2/10 MU 3 times per week for 2 months, 5 MU 3 times per week for 2 months and then 3 MU 3 times per week for 8 months, 48 weeks | Development of anti IFN antibodies | 72/96 | 0/19 0/19 | | | 0.00 (-0.10; 0.10)
Lopez-Alcorocho, 1997^85^ Intron A, Schering-Plough Inc, USA, 6/10 MU 3 times per week for 2 months, 5 MU 3 times per week for 2 months and then 3 MU 2 times per week for 2 months, 24 weeks | Intron A, Schering-Plough Inc, USA, 2/10 MU 3 times per week for 2 months, 5 MU 3 times per week for 2 months and then 3 MU 3 times per week for 8 months, 48 weeks | Loss HBV DNA | 24/48 | 4/19 5/19 | 21/26 | 0.80 (0.25; 2.53) | -0.05 (-0.32; 0.22) | -19
Lopez-Alcorocho, 1997^85^ Intron A, Schering-Plough Inc, USA, 6/10 MU 3 times per week for 2 months, 5 MU 3 times per week for 2 months and then 3 MU 2 times per week for 2 months, 24 weeks | Intron A, Schering-Plough Inc, USA, 2/10 MU 3 times per week for 2 months, 5 MU 3 times per week for 2 months and then 3 MU 3 times per week for 8 months, 48 weeks | Loss HBV DNA | 48/72 | 0/19 6/19 | 0/32 | 0.08 (0.00; 1.28) | -0.32 (-0.53; -0.10) | -3
Lopez-Alcorocho, 1997^85^ Intron A, Schering-Plough Inc, USA, 6/10 MU 3 times per week for 2 months, 5 MU 3 times per week for 2 months and then 3 MU 2 times per week for 2 months, 24 weeks | Intron A, Schering-Plough Inc, USA, 2/10 MU 3 times per week for 2 months, 5 MU 3 times per week for 2 months and then 3 MU 3 times per week for 8 months, 48 weeks | Loss HBV DNA | 72/96 | 2/19 5/19 | 11/26 | 0.40 (0.09; 1.81) | -0.16 (-0.40; 0.08) | -6
72/96 | 2/19 3/19 | 11/16 | 0.67 (0.13; 3.55) | -0.05 (-0.27; 0.16) | -19
Lampertico, 1997^84^ “IFN-a2b (Intron A, Schering-Plough, Milan, Italy)”, 3/6 MU 3 times per week, 96 weeks | No treatment, 96 weeks | Flare as rise in ALT levels >> 5 times ULN and/or rise in serum levels of HBV DNA > 100 picograms/mL | 96/96 | 4/21 15/21 | 19/71 | 0.27 (0.11; 0.67) | -0.52 (-0.78; -0.27) | -2
Lampertico, 1997^84^ “IFN-a2b (Intron A, Schering-Plough, Milan, Italy)”, 3/6 MU 3 times per week, 96 weeks | No treatment, 96 weeks | Hepatocellular carcinoma | 56/56 | 1/21 0/21 | 5/0 | 3.00 (0.13; 69.70) | 0.05 (-0.07; 0.17) | 21
Lampertico, 1997^84^ “IFN-a2b (Intron A, Schering-Plough, Milan, Italy)”, 3/6 MU 3 times per week, 96 weeks | No treatment, 96 weeks | Loss of HBV DNA by dot-blot assay and normal ALT | 96/96 | 8/21 2/21 | 38/10 | 4.00 (0.96; 16.66) | 0.29 (0.04; 0.53) | 3
Lampertico, 1997^84^ “IFN-a2b (Intron A, Schering-Plough, Milan, Italy)”, 3/6 MU 3 times per week, 96 weeks | No treatment, 96 weeks | 144/144 | 6/21 0/21 | 29/0 | 13.00 (0.78; 17.03) | 0.29 (0.09; 0.49) | 3
Lampertico, 1997^84^ “IFN-a2b (Intron A, Schering-Plough, Milan, Italy)”, 3/6 MU 3 times per week, 96 weeks | No treatment, 96 weeks | Discontinuation due to adverse effects | 96/96 | 5/21 0/21 | 24/0 | 11.00 (0.65; 87.17) | 0.24 (0.05; 0.43) | 4
Lampertico, 1997^84^ “IFN-a2b (Intron A, Schering-Plough, Milan, Italy)”, 3/6 MU 3 times per week, 96 weeks | No treatment, 96 weeks | Persistent headache | 96/96 | 1/21 0/21 | 5/0 | 3.00 (0.13; 69.70) | 0.05 (-0.07; 0.17) | 21
Lampertico, 1997^84^ “IFN-a2b (Intron A, Schering-Plough, Milan, Italy)”, 3/6 MU 3 times per week, 96 weeks | No treatment, 96 weeks | Persistent myalgia or arthralgia | 96/96 | 3/21 0/21 | 14/0 | 7.00 (0.38; 127.69) | 0.14 (-0.02; 0.31) | 7
Lampertico, 1997^84^ “IFN-a2b (Intron A, Schering-Plough, Milan, Italy)”, 3/6 MU 3 times per week, 96 weeks | No treatment, 96 weeks | Moderate psychological depression | 96/96 | 1/21 0/21 | 5/0 | 3.00 (0.13; 69.70) | 0.05 (-0.07; 0.17) | 21
Lampertico, 1997^84^ “IFN-a2b (Intron A, Schering-Plough, Milan, Italy)”, 3/6 MU 3 times per week, 96 weeks | No treatment, 96 weeks | Histology index score improved: 50 reduction of the total histology activity index | 96/96 | 7/21 2/21 | 33/10 | 3.50 (0.82; 14.93) | 0.24 (0.00; 0.48) | 4
Lampertico, 1997^84^ “IFN-a2b (Intron A, Schering-Plough, Milan, Italy)”, 3/6 MU 3 times per week, 96 weeks | No treatment, 96 weeks | Histology index score remained unchanged | 96/96 | 6/21 7/21 | 29/33 | 0.86 (0.35; 2.12) | -0.05 (-0.33; 0.23) | -21
Lampertico, 1997^84^ “IFN-a2b (Intron A, Schering-Plough, Milan, Italy)”, 3/6 MU 3 times per week, 96 weeks | No treatment, 96 weeks | Histology index score worsened | 96/96 | 0/21 4/21 | 0/19 | 0.11 (0.01; 1.94) | -0.19 (-0.37; -0.01) | -5
Lampertico, 1997^84^ “IFN-a2b (Intron A, Schering-Plough, Milan, Italy)”, 3/6 MU 3 times per week, 96 weeks | No treatment, 96 weeks | Loss of HBsAg | 96/96 | 0/21 0/21 | | | 0.00 (-0.09; 0.09)
Lampertico, 1997^84^ “IFN-a2b (Intron A, Schering-Plough, Milan, Italy)”, 3/6 MU 3 times per week, 96 weeks | No treatment, 96 weeks | 144/144 | 2/21 0/21 | 10/0 | 5.00 (0.25; 98.27) | 0.10 (-0.05; 0.24) | 10
Lampertico, 1997^84^ “IFN-a2b (Intron A, Schering-Plough, Milan, Italy)”, 3/6 MU 3 times per week, 96 weeks | No treatment, 96 weeks | Loss of HBsAg and/or HBV-DNA | 144/144 | 7/21 0/21 | 33/0 | 15.00 (0.91; 46.93) | 0.33 (0.13; 0.54) | 3
Lampertico, 1997^84^ “IFN-a2b (Intron A, Schering-Plough, Milan, Italy)”, 3/6 MU 3 times per week, 96 weeks | No treatment, 96 weeks | HBsAg seroconversion | 144/144 | 2/21 0/21 | 10/0 | 5.00 (0.25; 98.27) | 0.10 (-0.05; 0.24) | 10
Relapse-any increase in ALT above ULNand/or detection of serum HBV DNA in the followup period | 144/144 | 2/21 2/21 | 10/10 | 1.00 (0.16; 6.45) | 0.00 (-0.18; 0.18)
Mutimer, 1997^80^ Intron A, Schering-Plough Inc, USA, 4/10 MU 3 times per week Lamivudine, 150mg daily, 16 weeks | Intron A, Schering-Plough Inc, USA + lamivudine, 4 /10 MU 3 times weekly + 4 weeks placebo then 12 weeks lamivudine 100mg/day, 16 weeks | ALT normalization | 16/16 | 11/14 5/6 | 79/83 | 0.94 (0.60; 1.48) | -0.05 (-0.42; 0.32) | -21
Mutimer, 1997^80^ Intron A, Schering-Plough Inc, USA, 4/10 MU 3 times per week Lamivudine, 150mg daily, 16 weeks | Intron A, Schering-Plough Inc, USA + lamivudine, 4 /10 MU 3 times weekly + 4 weeks placebo then 12 weeks lamivudine 100mg/day, 16 weeks | Loss of HBV DNA | 16/16 | 14/14 6/6 | 100/100 | | 0.00 (-0.21; 0.21)
Mutimer, 1997^80^ Intron A, Schering-Plough Inc, USA, 4/10 MU 3 times per week Lamivudine, 150mg daily, 16 weeks | Intron A, Schering-Plough Inc, USA + lamivudine, 4 /10 MU 3 times weekly + 4 weeks placebo then 12 weeks lamivudine 100mg/day, 16 weeks | HBeAg negativity | 16/16 | 4/14 0/6 | 29/0 | 4.20 (0.26; 67.74) | 0.29 (-0.01; 0.59) | 3
Mutimer, 1997^80^ Intron A, Schering-Plough Inc, USA, 4/10 MU 3 times per week Lamivudine, 150mg daily, 16 weeks | Intron A, Schering-Plough Inc, USA + lamivudine, 4 /10 MU 3 times weekly + 4 weeks placebo then 12 weeks lamivudine 100mg/day, 16 weeks | Sustained loss of HBV DNA | 32/32 | 1/14 0/6 | 7/0 | 1.40 (0.06; 30.23) | 0.07 (-0.17; 0.32) | 14
HBeAg seroconversion | 32/32 | 4/14 0/6 | 29/0 | 4.20 (0.26; 67.74) | 0.29 (-0.01; 0.59) | 3
Janssen, 1999^83^ Recombinant IFN-a (alfa-2b, Intron-A; Schering-Plough, Kenilworth, NJ), 4/10 MU 3 times per week, 32 weeks | Discontinuation of treatment of Interferon Alfa 2b (10 MU IFN-a 3 times/week for 16 weeks) | Dose reduction due to depression, fatigue, hair loss, and headache | 32/32 | 7/61 0/57 | 11/0 | 14.03 (0.82; 40.23) | 0.11 (0.03; 0.20) | 9
Janssen, 1999^83^ Recombinant IFN-a (alfa-2b, Intron-A; Schering-Plough, Kenilworth, NJ), 4/10 MU 3 times per week, 32 weeks | Discontinuation of treatment of Interferon Alfa 2b (10 MU IFN-a 3 times/week for 16 weeks) | Discontinuation due to adverse effects | 32/32 | 3/61 0/57 | 5/0 | 6.55 (0.35; 124.05) | 0.05 (-0.01; 0.11) | 20
Janssen, 1999^83^ Recombinant IFN-a (alfa-2b, Intron-A; Schering-Plough, Kenilworth, NJ), 4/10 MU 3 times per week, 32 weeks | Discontinuation of treatment of Interferon Alfa 2b (10 MU IFN-a 3 times/week for 16 weeks) | Collapse after dizziness | 32/32 | 1/61 0/57 | 2/0 | 2.81 (0.12; 67.52) | 0.02 (-0.03; 0.06) | 61
Janssen, 1999^83^ Recombinant IFN-a (alfa-2b, Intron-A; Schering-Plough, Kenilworth, NJ), 4/10 MU 3 times per week, 32 weeks | Discontinuation of treatment of Interferon Alfa 2b (10 MU IFN-a 3 times/week for 16 weeks) | Sustained HBeAg and HBV-DNA negativity | 52/52 | 17/61 7/57 | 28/12 | 2.27 (1.02; 5.06) | 0.16 (0.01; 0.30) | 6
Janssen, 1999^83^ Recombinant IFN-a (alfa-2b, Intron-A; Schering-Plough, Kenilworth, NJ), 4/10 MU 3 times per week, 32 weeks | Discontinuation of treatment of Interferon Alfa 2b (10 MU IFN-a 3 times/week for 16 weeks) | Clearance of HBeAg with subsequent HBeAg reappearance | 52/52 | 1/61 2/57 | 2/4 | 0.47 (0.04; 5.01) | -0.02 (-0.08; 0.04) | -53
Lost HBsAg | 52/52 | 3/61 0/57 | 5/0 | 6.55 (0.35; 124.05) | 0.05 (-0.01; 0.11) | 20
Schalm, 2000^67^ Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4 /10 MU 3 times weekly 8 weeks lamivudine 100 mg/day followed by 16 weeks of lamivudine 100 mg/day and alpha interferon, 24 weeks | Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4 /10 MU 3 times per week, 24 weeks | ALT normalization <1.0 ULN | 24/24 | 62/75 58/69 | 83/84 | 0.98 (0.85; 1.14) | -0.01 (-0.14; 0.11) | -72
| Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4 /10 MU 3 times per week, 24 weeks | ALT normalization <1.0 ULN | 52/52 | 55/75 55/69 | 73/80 | 0.92 (0.77; 1.10) | -0.06 (-0.20; 0.07) | -16
64/64 | 50/75 50/69 | 67/72 | 0.92 (0.74; 1.14) | -0.06 (-0.21; 0.09) | -17
Schalm, 2000^67^ Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4 /10 MU 3 times weekly lamivudine, 100mg/day, 24 weeks | Lamivudine, 100 mg/day, 52 weeks | ALT normalization<1.0 ULN | 24/24 | 62/75 72/82 | 83/88 | 0.94 (0.83; 1.07) | -0.05 (-0.16; 0.06) | -19
Schalm, 2000^67^ Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4 /10 MU 3 times weekly lamivudine, 100mg/day, 24 weeks | Lamivudine, 100 mg/day, 52 weeks | ALT normalization<1.0 ULN | 52/52 | 55/75 58/82 | 73/71 | 1.04 (0.85; 1.26) | 0.03 (-0.11; 0.17) | 38
64/64 | 50/75 63/82 | 67/77 | 0.87 (0.71; 1.06) | -0.10 (-0.24; 0.04) | -10
Schalm, 2000^67^ Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4/10 MU 3 times weekly, 8 weeks of oral placebo once daily followed by 16 weeks of placebo once daily and interferon, 24 weeks | Lamivudine, 100 mg/day, 52 weeks | ALT normalization <1.0 ULN | 24/24 | 58/69 72/82 | 84/88 | 0.96 (0.84; 1.09) | -0.04 (-0.15; 0.07) | -27
| Lamivudine, 100 mg/day, 52 weeks | ALT normalization <1.0 ULN | 52/52 | 55/69 58/82 | 80/71 | 1.13 (0.94; 1.35) | 0.09 (-0.05; 0.23) | 11
64/64 | 50/69 63/82 | 72/77 | 0.94 (0.78; 1.14) | -0.04 (-0.18; 0.10) | -23
Schalm, 2000^67^ Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4/10 MU 3 times weekly 8 weeks of oral lamivudine 100 mg once daily followed by 16 weeks of lamivudine 100 mg once daily and alpha interferon mg/day, 24 weeks | Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4 /10 MU three times per week, 24 weeks | Viral respiratory infections | 52/52 | 32/76 37/70 | 42/53 | 0.80 (0.56; 1.12) | -0.11 (-0.27; 0.05) | -9
| Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4 /10 MU three times per week, 24 weeks | Headache | 52/52 | 71/76 47/70 | 93/67 | 1.39 (1.17; 1.66) | 0.26 (0.14; 0.39) | 4
| Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4 /10 MU three times per week, 24 weeks | Muscle pain | 52/52 | 36/76 40/70 | 47/57 | 0.83 (0.61; 1.13) | -0.10 (-0.26; 0.06) | -10
| Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4 /10 MU three times per week, 24 weeks | Abdominal discomfort and pain | 52/52 | 11/76 23/70 | 14/33 | 0.44 (0.23; 0.84) | -0.18 (-0.32; -0.05) | -5
| Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4 /10 MU three times per week, 24 weeks | Diarrhea | 52/52 | 14/76 16/70 | 18/23 | 0.81 (0.43; 1.53) | -0.04 (-0.18; 0.09) | -23
| Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4 /10 MU three times per week, 24 weeks | Malaise and fatigue | 52/52 | 66/76 70/70 | 87/100 | 0.87 (0.79; 0.95) | -0.13 (-0.21; -0.05) | -8
| Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4 /10 MU three times per week, 24 weeks | Arthralgia | 52/52 | 9/76 23/70 | 12/33 | 0.36 (0.18; 0.72) | -0.21 (-0.34; -0.08) | -5
| Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4 /10 MU three times per week, 24 weeks | Anorexia | 52/52 | 30/76 33/70 | 39/47 | 0.84 (0.58; 1.22) | -0.08 (-0.24; 0.08) | -13
| Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4 /10 MU three times per week, 24 weeks | Dizziness | 52/52 | 9/76 19/70 | 12/27 | 0.44 (0.21; 0.90) | -0.15 (-0.28; -0.03) | -7
| Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4 /10 MU three times per week, 24 weeks | Nausea and vomiting | 52/52 | 33/76 34/70 | 43/49 | 0.89 (0.63; 1.27) | -0.05 (-0.21; 0.11) | -19
| Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4 /10 MU three times per week, 24 weeks | Fever/chills | 52/52 | 46/76 43/70 | 61/61 | 0.99 (0.76; 1.28) | -0.01 (-0.17; 0.15) | -111
Hair loss and alopecia | 52/52 | 30/76 21/70 | 39/30 | 1.32 (0.84; 2.07) | 0.09 (-0.06; 0.25) | 11
Schalm, 2000^67^ Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4/10 MU 3 times weekly lamivudine, 100mg/day, 24 weeks | Lamivudine, 100 mg/day, 52 weeks | Viral respiratory infections | 52/52 | 32/76 25/84 | 42/30 | 1.41 (0.93; 2.16) | 0.12 (-0.02; 0.27) | 8
Schalm, 2000^67^ Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4/10 MU 3 times weekly lamivudine, 100mg/day, 24 weeks | Lamivudine, 100 mg/day, 52 weeks | Headache | 52/52 | 71/76 27/84 | 93/32 | 2.91 (2.12; 3.99) | 0.61 (0.50; 0.73) | 2
Schalm, 2000^67^ Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4/10 MU 3 times weekly lamivudine, 100mg/day, 24 weeks | Lamivudine, 100 mg/day, 52 weeks | Muscle pain | 52/52 | 36/76 11/84 | 47/13 | 3.62 (1.99; 6.59) | 0.34 (0.21; 0.48) | 3
Schalm, 2000^67^ Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4/10 MU 3 times weekly lamivudine, 100mg/day, 24 weeks | Lamivudine, 100 mg/day, 52 weeks | Abdominal discomfort and pain | 52/52 | 11/76 13/84 | 14/15 | 0.94 (0.45; 1.96) | -0.01 (-0.12; 0.10) | -100
Schalm, 2000^67^ Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4/10 MU 3 times weekly lamivudine, 100mg/day, 24 weeks | Lamivudine, 100 mg/day, 52 weeks | Diarrhea | 52/52 | 14/76 13/84 | 18/15 | 1.19 (0.60; 2.37) | 0.03 (-0.09; 0.15) | 34
Schalm, 2000^67^ Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4/10 MU 3 times weekly lamivudine, 100mg/day, 24 weeks | Lamivudine, 100 mg/day, 52 weeks | Malaise and fatigue | 52/52 | 66/76 35/84 | 87/42 | 2.08 (1.59; 2.72) | 0.45 (0.32; 0.58) | 2
Schalm, 2000^67^ Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4/10 MU 3 times weekly lamivudine, 100mg/day, 24 weeks | Lamivudine, 100 mg/day, 52 weeks | Arthralgia | 52/52 | 9/76 4/84 | 12/5 | 2.49 (0.80; 7.75) | 0.07 (-0.01; 0.16) | 14
Schalm, 2000^67^ Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4/10 MU 3 times weekly lamivudine, 100mg/day, 24 weeks | Lamivudine, 100 mg/day, 52 weeks | Anorexia | 52/52 | 30/76 4/84 | 39/5 | 8.29 (3.06; 22.44) | 0.35 (0.23; 0.47) | 3
Schalm, 2000^67^ Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4/10 MU 3 times weekly lamivudine, 100mg/day, 24 weeks | Lamivudine, 100 mg/day, 52 weeks | Dizziness | 52/52 | 9/76 8/84 | 12/10 | 1.24 (0.51; 3.06) | 0.02 (-0.07; 0.12) | 43
Schalm, 2000^67^ Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4/10 MU 3 times weekly lamivudine, 100mg/day, 24 weeks | Lamivudine, 100 mg/day, 52 weeks | Nausea and vomiting | 52/52 | 33/76 19/84 | 43/23 | 1.92 (1.20; 3.08) | 0.21 (0.07; 0.35) | 5
Schalm, 2000^67^ Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4/10 MU 3 times weekly lamivudine, 100mg/day, 24 weeks | Lamivudine, 100 mg/day, 52 weeks | Fever/chills | 52/52 | 46/76 6/84 | 61/7 | 8.47 (3.84; 18.71) | 0.53 (0.41; 0.66) | 2
Hair loss and alopecia | 52/52 | 30/76 8/84 | 39/10 | 4.14 (2.03; 8.48) | 0.30 (0.17; 0.43) | 3
Schalm, 2000^67^ Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4 /10 MU 3 times weekly, 8 weeks of oral placebo once daily followed by 16 weeks of placebo once daily and interferon, 24 weeks | Lamivudine, 100 mg/day, 52 weeks | Viral respiratory infections | 52/52 | 37/70 25/84 | 53/30 | 1.78 (1.20; 2.64) | 0.23 (0.08; 0.38) | 4
| Lamivudine, 100 mg/day, 52 weeks | Headache | 52/52 | 47/70 27/84 | 67/32 | 2.09 (1.47; 2.97) | 0.35 (0.20; 0.50) | 3
| Lamivudine, 100 mg/day, 52 weeks | Muscle pain | 52/52 | 40/70 11/84 | 57/13 | 4.36 (2.43; 7.85) | 0.44 (0.30; 0.58) | 2
| Lamivudine, 100 mg/day, 52 weeks | Abdominal discomfort and pain | 52/52 | 23/70 13/84 | 33/15 | 2.12 (1.16; 3.87) | 0.17 (0.04; 0.31) | 6
| Lamivudine, 100 mg/day, 52 weeks | Diarrhea | 52/52 | 16/70 13/84 | 23/15 | 1.48 (0.76; 2.86) | 0.07 (-0.05; 0.20) | 14
| Lamivudine, 100 mg/day, 52 weeks | Malaise and fatigue | 52/52 | 70/70 35/84 | 100/42 | 2.38 (1.85; 3.06) | 0.58 (0.48; 0.69) | 2
| Lamivudine, 100 mg/day, 52 weeks | Arthralgia | 52/52 | 23/70 4/84 | 33/5 | 6.90 (2.50; 19.01) | 0.28 (0.16; 0.40) | 4
| Lamivudine, 100 mg/day, 52 weeks | Anorexia | 52/52 | 33/70 4/84 | 47/5 | 9.90 (3.69; 26.59) | 0.42 (0.30; 0.55) | 2
| Lamivudine, 100 mg/day, 52 weeks | Dizziness | 52/52 | 19/70 8/84 | 27/10 | 2.85 (1.33; 6.11) | 0.18 (0.05; 0.30) | 6
| Lamivudine, 100 mg/day, 52 weeks | Nausea and vomiting | 52/52 | 34/70 19/84 | 49/23 | 2.15 (1.35; 3.41) | 0.26 (0.11; 0.41) | 4
| Lamivudine, 100 mg/day, 52 weeks | Fever/chills | 52/52 | 43/70 6/84 | 61/7 | 8.60 (3.89; 19.01) | 0.54 (0.42; 0.67) | 2
Hair loss and alopecia | 52/52 | 21/70 8/84 | 30/10 | 3.15 (1.49; 6.67) | 0.20 (0.08; 0.33) | 5
Schalm, 2000^67^ Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4/10 MU 3 times weekly 8 weeks of oral lamivudine 100 mg once daily followed by 16 weeks of lamivudine 100 mg once daily and alpha interferon mg/day, 24 weeks | Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4 /10 MU 3 times per week, 24 weeks | Discontinuation due to adverse effects | 24/24 | 2/76 0/70 | 3/0 | 4.61 (0.23; 94.40) | 0.03 (-0.02; 0.07) | 38
Schalm, 2000^67^ Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4 /10 MU 3 times weekly lamivudine, 100mg/day, 24 weeks | Lamivudine, 100 mg/day, 52 weeks | Discontinuation due to adverse effects | 24/52 | 2/76 3/84 | 3/4 | 0.74 (0.13; 4.29) | -0.01 (-0.06; 0.04) | -106
Schalm, 2000^67^ Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4/10 MU 3 times weekly, 8 weeks of oral placebo once daily followed by 16 weeks of placebo once daily and interferon, 24 weeks | Lamivudine, 100 mg/day, 52 weeks | Discontinuation due to adverse effects | 24/52 | 0/70 3/84 | 0/4 | 0.17 (0.01; 3.26) | -0.04 (-0.08; 0.01) | -28
Schalm, 2000^67^ Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4 /10 MU 3 times weekly 8 weeks of oral lamivudine 100 mg once daily followed by 16 weeks of lamivudine 100 mg once daily and alpha interferon mg/day, 24 weeks | Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4 /10 MU 3 times per week, 24 weeks | Hepatitis flares (ALT levels >500 IU/l and >2time from baseline) | 24/24 | 0/76 8/70 | 0/11 | 0.05 (0.00; 0.92) | -0.11 (-0.19; -0.04) | -9
Schalm, 2000^67^ Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4/10 MU 3 times weekly lamivudine, 100mg/day, 24 weeks | Lamivudine, 100 mg/day, 52 weeks | Hepatitis flares (ALT levels >500 IU/l and >2 times from baseline) | 24/52 | 0/76 10/84 | 0/12 | 0.05 (0.00; 0.88) | -0.12 (-0.19; -0.05) | -8
Schalm, 2000^67^ Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4 /10 MU 3 times weekly, 8 weeks of oral placebo once daily followed by 16 weeks of placebo once daily and interferon, 24 weeks | Lamivudine, 100 mg/day, 52 weeks | Hepatitis flares (ALT levels >500 IU/l and >2 times from baseline) | 24/52 | 8/70 10/84 | 11/12 | 0.96 (0.40; 2.30) | 0.00 (-0.11; 0.10) | -210
Schalm, 2000^67^ Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4/10 MU 3 times weekly lamivudine, 8 weeks of oral lamivudine 100 mg once daily followed by 16 weeks of lamivudine 100 mg once daily and alpha interferon mg/day, 24 weeks | Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4/10 MU 3 times per week, 24 weeks | Hepatitis flares (ALT levels >500 IU/l and >2 times from baseline) | 52/52 | 5/76 6/70 | 7/9 | 0.77 (0.25; 2.40) | -0.02 (-0.11; 0.07) | -50
Schalm, 2000^67^ Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4/10 MU 3 times weekly lamivudine, 100mg/day, 24 weeks | Lamivudine, 100 mg/day, 52 weeks | Hepatitis flares (ALT levels >500 IU/l and >2times from baseline) | 52/52 | 5/76 10/84 | 7/12 | 0.55 (0.20; 1.54) | -0.05 (-0.14; 0.04) | -19
Schalm, 2000^67^ Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4/10 MU 3 times weekly, 8 weeks of oral placebo once daily followed by 16 weeks of placebo once daily and interferon, 24 weeks | Lamivudine, 100 mg/day, 52 weeks | Hepatitis flares (ALT levels >500 IU/l and >2 times from baseline) | 52/52 | 6/70 10/84 | 9/12 | 0.72 (0.28; 1.88) | -0.03 (-0.13; 0.06) | -30
Schalm, 2000^67^ Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4 /10 MU 3 times weekly lamivudine, 8 weeks lamivudine 100 mg/day followed by 16 weeks of lamivudine 100 mg/day and alpha interferon, 24 weeks | Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4 /10 MU 3 times per week, 24 weeks | Histological response (reduction in Knodell score by at least 2 points) | 52/52 | 21/75 25/69 | 28/36 | 0.77 (0.48; 1.25) | -0.08 (-0.23; 0.07) | -12
Schalm, 2000^67^ Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4/10 MU 3 times weekly lamivudine, 100mg/day, 24 weeks | Lamivudine, 100 mg/day, 52 weeks | Histological response (reduction in Knodell score by at least 2 points) | 52/52 | 21/75 31/82 | 28/38 | 0.74 (0.47; 1.17) | -0.10 (-0.24; 0.05) | -10
Schalm, 2000^67^ Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4/10 MU 3 times weekly, 8 weeks of oral placebo once daily followed by 16 weeks of placebo once daily and interferon, 24 weeks | Lamivudine, 100 mg/day, 52 weeks | Histological response (reduction in Knodell score by at least 2 points) | 52/52 | 25/69 31/82 | 36/38 | 0.96 (0.63; 1.46) | -0.02 (-0.17; 0.14) | -64
Schalm, 2000^67^ Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4 /10 MU 3 times weekly lamivudine, 8 weeks lamivudine 100 mg/day followed by 16 weeks of lamivudine 100 mg/day and alpha interferon, 24 weeks | Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4 /10 MU 3 times per week, 24 weeks | Histological relapse (increase in Knodell score by at least 2 points) | 52/52 | 17/75 17/69 | 23/25 | 0.92 (0.51; 1.66) | -0.02 (-0.16; 0.12) | -51
Schalm, 2000^67^ Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4 /10 MU 3 times weekly Lamivudine, 100mg/day, 24 weeks | Lamivudine, 100 mg/day, 52 weeks | Histological relapse (increase in Knodell score by at least 2 points) | 52/52 | 17/75 7/82 | 23/9 | 2.66 (1.17; 6.04) | 0.14 (0.03; 0.25) | 7
Schalm, 2000^67^ Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4 /10 MU 3 times weekly, 8 weeks of oral placebo once daily followed by 16 weeks of placebo once daily and interferon, 24 weeks | Lamivudine, 100 mg/day, 52 weeks | Histological relapse (increase in Knodell score by at least 2 points) | 52/52 | 17/69 7/82 | 25/9 | 2.89 (1.27; 6.55) | 0.16 (0.04; 0.28) | 6
Schalm, 2000^67^ Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4/10 MU 3 times weekly Lamivudine, 8 weeks lamivudine 100 mg/day followed by 16 weeks of lamivudine 100 mg/day and alpha interferon, 24 weeks | Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4/10 MU 3 times per week, 24 weeks | HBeAg seroconversion: loss of HBeAg, development of antibodies to HBeAg, and undetectable HBV DNA | 24/24 | 68/75 64/69 | 91/93 | 0.98 (0.89; 1.08) | -0.02 (-0.11; 0.07) | -48
Schalm, 2000^67^ Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4 /10 MU 3 times weekly Lamivudine, 100mg/day, 24 weeks | Lamivudine, 100 mg/day, 52 weeks | HBeAg seroconversion: loss of HBeAg, development of antibodies to HBeAg, and undetectable HBV DNA | 24/24 | 68/75 80/82 | 91/98 | 0.93 (0.86; 1.01) | -0.07 (-0.14; 0.00) | -15
Schalm, 2000^67^ Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4 /10 MU 3 times weekly, 8 weeks lamivudine 100 mg/day followed by 16 weeks of lamivudine 100 mg/day and alpha interferon, 24 weeks | Lamivudine, 100 mg/day, 52 weeks | HBeAg seroconversion: loss of HBeAg, development of antibodies to HBeAg, and undetectable HBV DNA | 24/24 | 64/69 80/82 | 93/98 | 0.95 (0.88; 1.02) | -0.05 (-0.12; 0.02) | -21
Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4/10 MU 3 times per week, 24 weeks | HBeAg seroconversion: loss of HBeAg, development of antibodies to HBeAg, and undetectable HBV DNA | 52/52 | 68/75 64/69 | 91/93 | 0.98 (0.89; 1.08) | -0.02 (-0.11; 0.07) | -48
Schalm, 2000^67^ Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4 /10 MU three times weekly Lamivudine, 100mg/day, 24 weeks | Lamivudine, 100 mg/day, 52 weeks | HBeAg seroconversion: loss of HBeAg, development of antibodies to HBeAg, and undetectable HBV DNA. | 52/52 | 68/75 80/82 | 91/98 | 0.93 (0.86; 1.01) | -0.07 (-0.14; 0.00) | -15
Schalm, 2000^67^ Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4/10 MU 3 times weekly, 8 weeks of oral placebo once daily followed by 16 weeks of placebo once daily and interferon, 24 weeks | Lamivudine, 100 mg/day, 52 weeks | HBeAg seroconversion: loss of HBeAg, development of antibodies to HBeAg, and undetectable HBV DNA | 52/52 | 64/69 80/82 | 93/98 | 0.95 (0.88; 1.02) | -0.05 (-0.12; 0.02) | -21
Schalm, 2000^67^ Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4/10 MU 3 times weekly lamivudine, 8 weeks lamivudine 100 mg/day followed by 16 weeks of lamivudine 100 mg/day and alpha interferon, 24 weeks | Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4 /10 MU 3 times per week, 24 weeks | HBeAg seroconversion: loss of HBeAg, development of antibodies to HBeAg, and undetectable HBV DNA | 64/64 | 68/75 64/69 | 91/93 | 0.98 (0.89; 1.08) | -0.02 (-0.11; 0.07) | -48
Schalm, 2000^67^ Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4 /10 MU 3 times weekly lamivudine, 100mg/day, 24 weeks | Lamivudine, 100 mg/day, 52 weeks | HBeAg seroconversion: loss of HBeAg, development of antibodies to HBeAg, and undetectable HBV DNA | 64/64 | 68/75 80/82 | 91/98 | 0.93 (0.86; 1.01) | -0.07 (-0.14; 0.00) | -15
Schalm, 2000^67^ Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4 /10 MU 3 times weekly, 8 weeks of oral placebo once daily followed by 16 weeks of placebo once daily and interferon, 24 weeks | Lamivudine, 100 mg/day, 52 weeks | HBeAg seroconversion: loss of HBeAg, development of antibodies to HBeAg, and undetectable HBV DNA | 64/64 | 64/69 80/82 | 93/98 | 0.95 (0.88; 1.02) | -0.05 (-0.12; 0.02) | -21
Schalm, 2000^67^ Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4/10 MU 3 times weekly lamivudine, 8 weeks lamivudine 100 mg/day followed by 16 weeks of lamivudine 100 mg/day and alpha interferon, 24 weeks | Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4/10 MU 3 times per week, 24 weeks | HBeAg loss | 24/24 | 62/75 57/69 | 83/83 | 1.00 (0.86; 1.16) | 0.00 (-0.12; 0.12) | 1725
| Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4/10 MU 3 times per week, 24 weeks | HBeAg loss | 52/52 | 55/75 56/69 | 73/81 | 0.90 (0.76; 1.08) | -0.08 (-0.21; 0.06) | -13
| Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4/10 MU 3 times per week, 24 weeks | 64/64 | 55/75 48/69 | 73/70 | 1.05 (0.86; 1.30) | 0.04 (-0.11; 0.19) | 27
| Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4/10 MU 3 times per week, 24 weeks | HBV DNA loss, <3 pg/ml, Abbott HBV DNA test | 24/24 | 62/75 57/69 | 83/83 | 1.00 (0.86; 1.16) | 0.00 (-0.12; 0.12) | 1725
| Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4/10 MU 3 times per week, 24 weeks | HBV DNA loss, <3 pg/ml, Abbott HBV DNA test | 52/52 | 55/75 55/69 | 73/80 | 0.92 (0.77; 1.10) | -0.06 (-0.20; 0.07) | -16
64/64 | 55/75 49/69 | 73/71 | 1.03 (0.84; 1.27) | 0.02 (-0.12; 0.17) | 43
Schalm, 2000^67^ Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4/10 MU 3 times weekly lamivudine, 100mg/day, 24 weeks | Lamivudine, 100 mg/day, 52 weeks | HBeAg loss | 24/24 | 62/75 70/82 | 83/85 | 0.97 (0.84; 1.11) | -0.03 (-0.14; 0.09) | -37
Schalm, 2000^67^ Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4/10 MU 3 times weekly lamivudine, 100mg/day, 24 weeks | Lamivudine, 100 mg/day, 52 weeks | HBeAg loss | 52/52 | 55/75 60/82 | 73/73 | 1.00 (0.83; 1.21) | 0.00 (-0.14; 0.14) | 615
Schalm, 2000^67^ Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4/10 MU 3 times weekly lamivudine, 100mg/day, 24 weeks | Lamivudine, 100 mg/day, 52 weeks | 64/64 | 55/75 62/82 | 73/76 | 0.97 (0.81; 1.17) | -0.02 (-0.16; 0.11) | -44
Schalm, 2000^67^ Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4/10 MU 3 times weekly lamivudine, 100mg/day, 24 weeks | Lamivudine, 100 mg/day, 52 weeks | HBV DNA loss, <3 pg/ml, Abbott HBV DNA test | 24/24 | 62/75 70/82 | 83/85 | 0.97 (0.84; 1.11) | -0.03 (-0.14; 0.09) | -37
Schalm, 2000^67^ Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4/10 MU 3 times weekly lamivudine, 100mg/day, 24 weeks | Lamivudine, 100 mg/day, 52 weeks | HBV DNA loss, <3 pg/ml, Abbott HBV DNA test | 52/52 | 55/75 60/82 | 73/73 | 1.00 (0.83; 1.21) | 0.00 (-0.14; 0.14) | 615
64/64 | 55/75 63/82 | 73/77 | 0.95 (0.80; 1.14) | -0.03 (-0.17; 0.10) | -29
Schalm, 2000^67^ Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4/10 MU 3 times weekly, 8 weeks of oral placebo once daily followed by 16 weeks of placebo once daily and interferon, 24 weeks | Lamivudine, 100 mg/day, 52 weeks | HBeAg loss | 24/24 | 57/69 70/82 | 83/85 | 0.97 (0.84; 1.11) | -0.03 (-0.15; 0.09) | -36
| Lamivudine, 100 mg/day, 52 weeks | HBeAg loss | 52/52 | 56/69 60/82 | 81/73 | 1.11 (0.93; 1.32) | 0.08 (-0.05; 0.21) | 13
| Lamivudine, 100 mg/day, 52 weeks | 64/64 | 48/69 62/82 | 70/76 | 0.92 (0.75; 1.12) | -0.06 (-0.20; 0.08) | -17
| Lamivudine, 100 mg/day, 52 weeks | HBV DNA loss, <3 pg/ml, Abbott HBV DNA test | 24/24 | 57/69 70/82 | 83/85 | 0.97 (0.84; 1.11) | -0.03 (-0.15; 0.09) | -36
| Lamivudine, 100 mg/day, 52 weeks | HBV DNA loss, <3 pg/ml, Abbott HBV DNA test | 52/52 | 55/69 60/82 | 80/73 | 1.09 (0.91; 1.30) | 0.07 (-0.07; 0.20) | 15
64/64 | 49/69 63/82 | 71/77 | 0.92 (0.76; 1.12) | -0.06 (-0.20; 0.08) | -17
Schalm, 2000^67^ Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4/10 MU 3 times weekly lamivudine, 8 weeks of oral lamivudine 100 mg once daily followed by 16 weeks of lamivudine 100 mg once daily and alpha interferon, 24 weeks | Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4/10 MU 3 times per week, 24 weeks | Incidence of YMDD | 52/52 | 0/75 0/69 | | | 0.00 (-0.03; 0.03)
Schalm, 2000^67^ Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4/10 MU 3 times weekly lamivudine, 100mg/day, 24 weeks | Lamivudine, 100 mg/day, 52 weeks | Incidence of YMDD | 52/52 | 0/75 19/82 | 0/23 | 0.03 (0.00; 0.46) | -0.23 (-0.32; -0.14) | -4
Schalm, 2000^67^ Alpha interferon (Intron A, Schering Plough, Kenilworth, USA), 4/10 MU 3 times weekly, 8 weeks of oral placebo once daily followed by 16 weeks of placebo once daily and interferon, 24 weeks | Lamivudine, 100 mg/day, 52 weeks | Incidence of YMDD | 52/52 | 0/69 19/82 | 0/23 | 0.03 (0.00; 0.49) | -0.23 (-0.33; -0.14) | -4
Barbaro, 2001^66^ Recombinant interferon alpha-2b (Intron A, Schering Plough, Kenilworth, NJ, USA), 4/9 MU 3 times per week Lamivudine (Glaxo-Wellcome Inc, Research Triangle Park, NC), 100mg/day, 24 weeks | Lamivudine (Glaxo-Wellcome Inc, Research Triangle Park, NC), 100 mg/day, 52 weeks | ALT: 3.1 to 10 times the baseline value and > 10 times the baseline value, respectively | 72/100 | 15/76 9/75 | 20/12 | 1.64 (0.77; 3.53) | 0.08 (-0.04; 0.19) | 13
| Lamivudine (Glaxo-Wellcome Inc, Research Triangle Park, NC), 100 mg/day, 52 weeks | Albumin: 2.0–2.4 g/dl and < 2.0 g/dl | 72/100 | 2/76 2/75 | 3/3 | 0.99 (0.14; 6.82) | 0.00 (-0.05; 0.05) | -2850
| Lamivudine (Glaxo-Wellcome Inc, Research Triangle Park, NC), 100 mg/day, 52 weeks | Amylase: value 3.1 to 10 times the baseline value and >10 times the baseline value | 72/100 | 2/76 1/75 | 3/1 | 1.97 (0.18; 21.31) | 0.01 (-0.03; 0.06) | 77
| Lamivudine (Glaxo-Wellcome Inc, Research Triangle Park, NC), 100 mg/day, 52 weeks | Lipase: value 2.6 to 5 times ULNand more >5 times the upper limit of normal | 72/100 | 4/76 2/75 | 5/3 | 1.97 (0.37; 10.45) | 0.03 (-0.04; 0.09) | 39
| Lamivudine (Glaxo-Wellcome Inc, Research Triangle Park, NC), 100 mg/day, 52 weeks | Creatine kinase: value 7 to 9.9 times the baseline value and at least 10 times the baseline value | 72/100 | 6/76 5/75 | 8/7 | 1.18 (0.38; 3.71) | 0.01 (-0.07; 0.10) | 81
| Lamivudine (Glaxo-Wellcome Inc, Research Triangle Park, NC), 100 mg/day, 52 weeks | Platelets: value of 20,000–49,000/mm3 and < 20,000/mm3 | 72/100 | 2/76 2/75 | 3/3 | 0.99 (0.14; 6.82) | 0.00 (-0.05; 0.05) | -2850
| Lamivudine (Glaxo-Wellcome Inc, Research Triangle Park, NC), 100 mg/day, 52 weeks | ALT levels returned to normal during treatment and remained so during the followup period | 72/100 | 28/76 17/75 | 37/23 | 1.63 (0.97; 2.71) | 0.14 (0.00; 0.29) | 7
| Lamivudine (Glaxo-Wellcome Inc, Research Triangle Park, NC), 100 mg/day, 52 weeks | Influenza-like symptoms | 72/100 | 47/76 12/75 | 62/16 | 3.87 (2.23; 6.68) | 0.46 (0.32; 0.60) | 2
| Lamivudine (Glaxo-Wellcome Inc, Research Triangle Park, NC), 100 mg/day, 52 weeks | Malaise or fatigue | 72/100 | 8/76 8/75 | 11/11 | 0.99 (0.39; 2.49) | 0.00 (-0.10; 0.10) | -713
| Lamivudine (Glaxo-Wellcome Inc, Research Triangle Park, NC), 100 mg/day, 52 weeks | Nausea or vomiting | 72/100 | 7/76 5/75 | 9/7 | 1.38 (0.46; 4.16) | 0.03 (-0.06; 0.11) | 39
| Lamivudine (Glaxo-Wellcome Inc, Research Triangle Park, NC), 100 mg/day, 52 weeks | Headache | 72/100 | 8/76 7/75 | 11/9 | 1.13 (0.43; 2.95) | 0.01 (-0.08; 0.11) | 84
| Lamivudine (Glaxo-Wellcome Inc, Research Triangle Park, NC), 100 mg/day, 52 weeks | Abdominal discomfort | 72/100 | 5/76 4/75 | 7/5 | 1.23 (0.34; 4.42) | 0.01 (-0.06; 0.09) | 80
| Lamivudine (Glaxo-Wellcome Inc, Research Triangle Park, NC), 100 mg/day, 52 weeks | Skin rash | 72/100 | 6/76 5/75 | 8/7 | 1.18 (0.38; 3.71) | 0.01 (-0.07; 0.10) | 81
| Lamivudine (Glaxo-Wellcome Inc, Research Triangle Park, NC), 100 mg/day, 52 weeks | Diarrhea | 72/100 | 4/76 5/75 | 5/7 | 0.79 (0.22; 2.83) | -0.01 (-0.09; 0.06) | -71
| Lamivudine (Glaxo-Wellcome Inc, Research Triangle Park, NC), 100 mg/day, 52 weeks | Withdrawal from the study because of side effects | 39731 | 3/76 4/75 | 4/5 | 0.74 (0.17; 3.20) | -0.01 (-0.08; 0.05) | -72
| Lamivudine (Glaxo-Wellcome Inc, Research Triangle Park, NC), 100 mg/day, 52 weeks | improvement of the inflammation score defined as a reduction of at least 2 points in the score as compared to baseline | 24/52 | 35/76 20/75 | 46/27 | 1.73 (1.10; 2.70) | 0.19 (0.04; 0.34) | 5
| Lamivudine (Glaxo-Wellcome Inc, Research Triangle Park, NC), 100 mg/day, 52 weeks | Improvement of fibrosis score defined as a reduction of at least 2 points in the score as compared to baseline | 24/52 | 32/76 18/75 | 42/24 | 1.75 (1.08; 2.84) | 0.18 (0.03; 0.33) | 6
| Lamivudine (Glaxo-Wellcome Inc, Research Triangle Park, NC), 100 mg/day, 52 weeks | HBeAg seroconversion and undetectable levels of HBV DNA | 24/52 | 27/76 14/75 | 36/19 | 1.90 (1.09; 3.34) | 0.17 (0.03; 0.31) | 6
| Lamivudine (Glaxo-Wellcome Inc, Research Triangle Park, NC), 100 mg/day, 52 weeks | Undetectable HBV DNA on at least one occasion | 24/52 | 65/76 51/75 | 85/68 | 1.26 (1.05; 1.51) | 0.18 (0.04; 0.31) | 6
| Lamivudine (Glaxo-Wellcome Inc, Research Triangle Park, NC), 100 mg/day, 52 weeks | Viral breakthrough: HBV DNA initially became negative but reappeared after 16 and 24 weeks of therapy | 24/52 | 3/76 2/75 | 4/3 | 1.48 (0.25; 8.61) | 0.01 (-0.04; 0.07) | 78
| Lamivudine (Glaxo-Wellcome Inc, Research Triangle Park, NC), 100 mg/day, 52 weeks | Relapse: detectable levels of HBeAg and HBV DNA within 12 weeks after treatment | 39794 | 2/76 3/75 | 3/4 | 0.66 (0.11; 3.83) | -0.01 (-0.07; 0.04) | -73
| Lamivudine (Glaxo-Wellcome Inc, Research Triangle Park, NC), 100 mg/day, 52 weeks | HBeAg seroconversion and undetectable levels of HBV DNA | 72/100 | 25/76 11/75 | 33/15 | 2.24 (1.19; 4.23) | 0.18 (0.05; 0.31) | 5
| Lamivudine (Glaxo-Wellcome Inc, Research Triangle Park, NC), 100 mg/day, 52 weeks | Undetectable levels of HBsAg | 72/100 | 0/76 0/75 | | | 0.00 (-0.03; 0.03)
| Lamivudine (Glaxo-Wellcome Inc, Research Triangle Park, NC), 100 mg/day, 52 weeks | Median reduction in the HBsAg concentrations | 72/100 | 18/76 9/75 | 24/12 | 1.97 (0.95; 4.11) | 0.12 (0.00; 0.24) | 9
Genotypic mutations in the YMDD locus assessed in HBV DNA amplified by polymerase chain reaction | 24/52 | 9/76 11/75 | 12/15 | 0.81 (0.36; 1.84) | -0.03 (-0.14; 0.08) | -35
Perrillo, 2002^104^ Intron A; Schering-Plough, Kenilworth, NJ, 4/10 MU 3 times per week for 16 weeks Lamivudine, 100mg/day for 8 weeks, then combined with Interferon until week 24, 24 weeks | Intron A; Schering-Plough, Kenilworth, NJ, 8 weeks of oral placebo then Placebo+ interferon 10 MU 3 times weekly for 16 weeks, 24 weeks | HBeAg loss rrespective of HBV-DNA status | 52/52 | 35/135 15/68 | 26/22 | 1.18 (0.69; 2.00) | 0.04 (-0.08; 0.16) | 26
Perrillo, 2002^104^ Intron A; Schering-Plough, Kenilworth, NJ, 4/10 MU 3 times per week for 16 weeks Lamivudine, 100mg/day for 8 weeks, then combined with Interferon until week 24, 24 weeks | Lamivudine, 100 mg/day, 52 weeks | HBeAg loss irrespective of HBV-DNA status | 52/52 | 35/135 102/406 | 26/25 | 1.03 (0.74; 1.44) | 0.01 (-0.08; 0.09) | 125
Placebo, 52 weeks | HBeAg loss irrespective of HBV-DNA status | 52/52 | 35/135 20/196 | 26/10 | 2.54 (1.54; 4.20) | 0.16 (0.07; 0.24) | 6
Perrillo, 2002^104^ Intron A; Schering-Plough, Kenilworth, NJ, 8 weeks of oral placebo then Placebo+ interferon 10 MU 3 times weekly for 16 weeks, 24 weeks | Lamivudine, 100 mg/day, 24 weeks | HBeAg loss irrespective of HBV-DNA status | 52/52 | 15/68 102/406 | 22/25 | 0.88 (0.54; 1.42) | -0.03 (-0.14; 0.08) | -33
Placebo, 52 weeks | HBeAg loss irrespective of HBV-DNA status | 52/52 | 15/68 20/196 | 22/10 | 2.16 (1.17; 3.98) | 0.12 (0.01; 0.23) | 8
Perrillo, 2002^104^ Intron A; Schering-Plough, Kenilworth, NJ, 4/10 MU 3 times weekly for 16 weeks Lamivudine, 100mg/day for 8 weeks, then combined with Interferon until week 24, 24 weeks | Intron A; Schering-Plough, Kenilworth, NJ, 8 weeks of oral placebo then placebo+ interferon 10 MU 3 times weekly for 16 weeks, 24 weeks | HBeAg seroconversionand HBV DNA loss | 52/52 | 27/135 12/68 | 20/18 | 1.13 (0.61; 2.09) | 0.02 (-0.09; 0.14) | 43
Perrillo, 2002^104^ Intron A; Schering-Plough, Kenilworth, NJ, 4/10 MU 3 times weekly for 16 weeks Lamivudine, 100mg/day for 8 weeks, then combined with Interferon until week 24, 24 weeks | Lamivudine, 100 mg/day, 52 weeks | HBeAg seroconversion and HBV DNA loss | 52/52 | 27/135 66/406 | 20/16 | 1.23 (0.82; 1.84) | 0.04 (-0.04; 0.11) | 27
Placebo, 0, 52 weeks | HBeAg seroconversion and HBV DNA loss | 52/52 | 27/135 14/196 | 20/7 | 2.80 (1.53; 5.14) | 0.13 (0.05; 0.21) | 8
Perrillo, 2002^104^ Intron A; Schering-Plough, Kenilworth, NJ, 8 weeks of oral placebo then placebo+ interferon 10 MU 3 times weekly for 16 weeks, 24 weeks | Lamivudine, 100 mg/day, 24 weeks | HBeAg seroconversion and HBV DNA loss | 52/52 | 12/68 66/406 | 18/16 | 1.09 (0.62; 1.90) | 0.01 (-0.08; 0.11) | 72
Placebo, 52 weeks | HBeAg seroconversion and HBV DNA loss | 52/52 | 12/68 14/196 | 18/7 | 2.47 (1.20; 5.08) | 0.11 (0.01; 0.20) | 10
Chung, 2003^82^ Recombinant IFN-Alfa 2b (Intron A; Schering-Plough, Kenilworth, NJ, USA), 4 /5 MU/m2 3 times a week for 6 months + prolonged to maintain negative serum HBV-DNA levels for the next 6 months in patients who became HBV-DNA-negative following IFN therapy, 48 weeks | Recombinant IFN-Alfa 2b (Intron A; Schering-Plough, Kenilworth, NJ, USA), 4/5 MU/m2 three times per week, 24 weeks | Normalization of ALT | 48/24 | 20/30 28/35 | 67/80 | 0.83 (0.62; 1.13) | -0.13 (-0.35; 0.08) | -8
| Recombinant IFN-Alfa 2b (Intron A; Schering-Plough, Kenilworth, NJ, USA), 4/5 MU/m2 three times per week, 24 weeks | 96/72 | 14/30 9/35 | 47/26 | 1.81 (0.92; 3.58) | 0.21 (-0.02; 0.44) | 5
| Recombinant IFN-Alfa 2b (Intron A; Schering-Plough, Kenilworth, NJ, USA), 4/5 MU/m2 three times per week, 24 weeks | Discontinuation due to adverse effects | 48/24 | 0/30 0/35 | | | 0.00 (-0.06; 0.06)
| Recombinant IFN-Alfa 2b (Intron A; Schering-Plough, Kenilworth, NJ, USA), 4/5 MU/m2 three times per week, 24 weeks | Loss of HBV-DNA | 48/24 | 16/30 18/35 | 53/51 | 1.04 (0.65; 1.65) | 0.02 (-0.22; 0.26) | 53
| Recombinant IFN-Alfa 2b (Intron A; Schering-Plough, Kenilworth, NJ, USA), 4/5 MU/m2 three times per week, 24 weeks | Loss of HBeAg | 48/24 | 6/30 12/35 | 20/34 | 0.58 (0.25; 1.36) | -0.14 (-0.36; 0.07) | -7
| Recombinant IFN-Alfa 2b (Intron A; Schering-Plough, Kenilworth, NJ, USA), 4/5 MU/m2 three times per week, 24 weeks | Appearance of anti-HBe | 48/24 | 8/30 13/35 | 27/37 | 0.72 (0.34; 1.49) | -0.10 (-0.33; 0.12) | -10
| Recombinant IFN-Alfa 2b (Intron A; Schering-Plough, Kenilworth, NJ, USA), 4/5 MU/m2 three times per week, 24 weeks | Loss of HBV-DNA | 96/72 | 15/30 10/35 | 50/29 | 1.75 (0.93; 3.30) | 0.21 (-0.02; 0.45) | 5
| Recombinant IFN-Alfa 2b (Intron A; Schering-Plough, Kenilworth, NJ, USA), 4/5 MU/m2 three times per week, 24 weeks | Loss of HBeAg | 96/72 | 8/30 9/35 | 27/26 | 1.04 (0.46; 2.35) | 0.01 (-0.20; 0.22) | 105
| Recombinant IFN-Alfa 2b (Intron A; Schering-Plough, Kenilworth, NJ, USA), 4/5 MU/m2 three times per week, 24 weeks | Appearance of anti-HBe | 96/72 | 8/30 10/35 | 27/29 | 0.93 (0.42; 2.06) | -0.02 (-0.24; 0.20) | -53
Loss of serum HBsAg | 96/72 | 0/30 0/35 | | | 0.00 (-0.06; 0.06)
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Placebo, 52 weeks | Normal ALT | 52/52 | 11/63 8/56 | 17/14 | 1.22 (0.53; 2.82) | 0.03 (-0.10; 0.16) | 32
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Lamivudine, 100 mg/daily, 52 weeks | Normal ALT | 52/52 | 11/63 51/119 | 17/43 | 0.41 (0.23; 0.72) | -0.25 (-0.38; -0.12) | -4
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Placebo, 52 weeks | Discontinuation due to adverse effects | 52/52 | 1/63 5/56 | 2/9 | 0.18 (0.02; 1.48) | -0.07 (-0.15; 0.01) | -14
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Lamivudine, 100 mg/daily, 52 weeks | Discontinuation due to adverse effects | 52/52 | 1/63 3/119 | 2/3 | 0.63 (0.07; 5.93) | -0.01 (-0.05; 0.03) | -107
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Placebo, 52 weeks | Malaise/fatigue | 52/52 | 60/63 18/56 | 95/32 | 2.96 (2.02; 4.35) | 0.63 (0.50; 0.76) | 2
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Placebo, 52 weeks | Fever | 52/52 | 60/63 0/56 | 95/0 | 107.77 (6.82; 1703.11) | 0.95 (0.89; 1.01) | 1
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Placebo, 52 weeks | Headache | 52/52 | 48/63 13/56 | 76/23 | 3.28 (2.00; 5.39) | 0.53 (0.38; 0.68) | 2
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Placebo, 52 weeks | Nausea/vomiting | 52/52 | 37/63 11/56 | 59/20 | 2.99 (1.69; 5.28) | 0.39 (0.23; 0.55) | 3
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Placebo, 52 weeks | Hair loss/alopecia | 52/52 | 30/63 2/56 | 48/4 | 13.33 (3.34; 53.28) | 0.44 (0.31; 0.57) | 2
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Placebo, 52 weeks | Muscle pain | 52/52 | 29/63 5/56 | 46/9 | 5.16 (2.14; 12.41) | 0.37 (0.23; 0.51) | 3
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Placebo, 52 weeks | Viral respiratory infections | 52/52 | 22/63 0/56 | 35/0 | 40.08 (2.49; 645.77) | 0.35 (0.23; 0.47) | 3
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Placebo, 52 weeks | Feeding problems | 52/52 | 19/63 2/56 | 30/4 | 8.44 (2.06; 34.65) | 0.27 (0.14; 0.39) | 4
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Placebo, 52 weeks | Depression | 52/52 | 17/63 2/56 | 27/4 | 7.56 (1.83; 31.27) | 0.23 (0.11; 0.35) | 4
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Placebo, 52 weeks | Decreased WBCs | 52/52 | 16/63 0/56 | 25/0 | 29.39 (1.80; 478.87) | 0.25 (0.14; 0.36) | 4
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Placebo, 52 weeks | Rheumatism | 52/52 | 16/63 2/56 | 25/4 | 7.11 (1.71; 29.57) | 0.22 (0.10; 0.34) | 5
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Placebo, 52 weeks | Diarrhea | 52/52 | 13/63 0/56 | 21/0 | 24.05 (1.46; 395.45) | 0.21 (0.10; 0.31) | 5
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Placebo, 52 weeks | Abnormal ALT/AST | 52/52 | 10/63 9/56 | 16/16 | 0.99 (0.43; 2.25) | 0.00 (-0.13; 0.13) | -504
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Placebo, 52 weeks | Pain | 52/52 | 10/63 4/56 | 16/7 | 2.22 (0.74; 6.69) | 0.09 (-0.03; 0.20) | 11
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Placebo, 52 weeks | Musculoskeletal pain | 52/52 | 10/63 2/56 | 16/4 | 4.44 (1.02; 19.42) | 0.12 (0.02; 0.23) | 8
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Abnormal enzymes (amylase/CPK) | 52/52 | 8/63 4/56 | 13/7 | 1.78 (0.57; 5.59) | 0.06 (-0.05; 0.16) | 18
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Lamivudine, 100 mg/daily, 52 weeks | Malaise/fatigue | 52/52 | 60/63 32/119 | 95/27 | 3.54 (2.62; 4.79) | 0.68 (0.59; 0.78) | 1
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Lamivudine, 100 mg/daily, 52 weeks | Fever | 52/52 | 60/63 9/119 | 95/8 | 12.59 (6.70; 23.66) | 0.88 (0.81; 0.95) | 1
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Lamivudine, 100 mg/daily, 52 weeks | Headache | 52/52 | 48/63 18/119 | 76/15 | 5.04 (3.22; 7.88) | 0.61 (0.49; 0.73) | 2
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Lamivudine, 100 mg/daily, 52 weeks | Nausea/vomiting | 52/52 | 37/63 20/119 | 59/17 | 3.49 (2.23; 5.48) | 0.42 (0.28; 0.56) | 2
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Lamivudine, 100 mg/daily, 52 weeks | Hair loss/alopecia | 52/52 | 30/63 2/119 | 48/2 | 28.33 (7.00; 114.71) | 0.46 (0.33; 0.58) | 2
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Lamivudine, 100 mg/daily, 52 weeks | Muscle pain | 52/52 | 29/63 22/119 | 46/18 | 2.49 (1.57; 3.95) | 0.28 (0.13; 0.42) | 4
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Lamivudine, 100 mg/daily, 52 weeks | Viral respiratory infections | 52/52 | 22/63 3/119 | 35/3 | 13.85 (4.31; 44.50) | 0.32 (0.20; 0.45) | 3
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Lamivudine, 100 mg/daily, 52 weeks | Feeding problems | 52/52 | 19/63 2/119 | 30/2 | 17.94 (4.32; 74.59) | 0.28 (0.17; 0.40) | 4
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Lamivudine, 100 mg/daily, 52 weeks | Depression | 52/52 | 17/63 5/119 | 27/4 | 6.42 (2.49; 16.59) | 0.23 (0.11; 0.34) | 4
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Lamivudine, 100 mg/daily, 52 weeks | Decreased WBCs | 52/52 | 16/63 1/119 | 25/1 | 30.22 (4.10; 222.66) | 0.25 (0.14; 0.35) | 4
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Lamivudine, 100 mg/daily, 52 weeks | Rheumatism | 52/52 | 16/63 6/119 | 25/5 | 5.04 (2.07; 12.23) | 0.20 (0.09; 0.32) | 5
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Lamivudine, 100 mg/daily, 52 weeks | Diarrhea | 52/52 | 13/63 15/119 | 21/13 | 1.64 (0.83; 3.22) | 0.08 (-0.04; 0.20) | 12
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Lamivudine, 100 mg/daily, 52 weeks | Abnormal ALT/AST | 52/52 | 10/63 22/119 | 16/18 | 0.86 (0.43; 1.70) | -0.03 (-0.14; 0.09) | -38
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Lamivudine, 100 mg/daily, 52 weeks | Pain | 52/52 | 10/63 1/119 | 16/1 | 18.89 (2.47; 144.23) | 0.15 (0.06; 0.24) | 7
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Lamivudine, 100 mg/daily, 52 weeks | Musculoskeletal pain | 52/52 | 10/63 1/119 | 16/1 | 18.89 (2.47; 144.23) | 0.15 (0.06; 0.24) | 7
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Abnormal enzymes (amylase/CPK) | 52/52 | 8/63 19/119 | 13/16 | 0.80 (0.37; 1.71) | -0.03 (-0.14; 0.07) | -31
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Placebo, 52 weeks | ALT >2 at baseline and >500U/l | 52/52 | 0/63 4/56 | 0/7 | 0.10 (0.01; 1.80) | -0.07 (-0.14; 0.00) | -14
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Lamivudine, 100 mg/daily, 52 weeks | ALT >2 at baseline and >500U/l | 52/52 | 0/63 9/119 | 0/8 | 0.10 (0.01; 1.67) | -0.08 (-0.13; -0.02) | -13
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Placebo, 52 weeks | ALT >2 at baseline and >500U/l | 68/68 | 1/63 2/56 | 2/4 | 0.44 (0.04; 4.77) | -0.02 (-0.08; 0.04) | -50
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Lamivudine, 100 mg/daily, 52 weeks | ALT >2 at baseline and >500U/l | 68/68 | 1/63 3/119 | 2/3 | 0.63 (0.07; 5.93) | -0.01 (-0.05; 0.03) | -107
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Placebo, 52 weeks | Histological response: reduction in HAI score >2 | 52/52 | 20/63 14/56 | 32/25 | 1.27 (0.71; 2.27) | 0.07 (-0.09; 0.23) | 15
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Lamivudine, 100 mg/daily, 52 weeks | Histological response: reduction in HAI score >2 | 52/52 | 20/63 62/119 | 32/52 | 0.61 (0.41; 0.91) | -0.20 (-0.35; -0.06) | -5
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Placebo, 52 weeks | Worsening in histology: increase in HAI by >2 scores | 52/52 | 13/63 9/56 | 21/16 | 1.28 (0.59; 2.77) | 0.05 (-0.09; 0.18) | 22
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Lamivudine, 100 mg/daily, 52 weeks | Worsening in histology: increase in HAI by >2 scores | 52/52 | 13/63 8/119 | 21/7 | 3.07 (1.34; 7.01) | 0.14 (0.03; 0.25) | 7
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Placebo, 52 weeks | Improved necroinflammatory activity | 52/52 | 21/63 16/56 | 33/29 | 1.17 (0.68; 2.01) | 0.05 (-0.12; 0.21) | 21
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Lamivudine, 100 mg/daily, 52 weeks | Improved necroinflammatory activity | 52/52 | 21/63 63/119 | 33/53 | 0.63 (0.43; 0.93) | -0.20 (-0.34; -0.05) | -5
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Placebo, 52 weeks | Worsening of fibrosis | 52/52 | 8/63 3/56 | 13/5 | 2.37 (0.66; 8.50) | 0.07 (-0.03; 0.17) | 14
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Lamivudine, 100 mg/daily, 52 weeks | Worsening of fibrosis | 52/52 | 8/63 4/119 | 13/3 | 3.78 (1.18; 12.06) | 0.09 (0.01; 0.18) | 11
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Placebo, 52 weeks | HBeAg loss | 52/52 | 13/63 7/56 | 21/12 | 1.65 (0.71; 3.84) | 0.08 (-0.05; 0.21) | 12
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Lamivudine, 100 mg/daily, 52 weeks | HBeAg loss | 52/52 | 13/63 38/119 | 21/32 | 0.65 (0.37; 1.12) | -0.11 (-0.24; 0.02) | -9
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Placebo, 52 weeks | HBeAg loss | 68/68 | 11/63 9/56 | 17/16 | 1.09 (0.49; 2.43) | 0.01 (-0.12; 0.15) | 72
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Lamivudine, 100 mg/daily, 52 weeks | HBeAg loss | 68/68 | 11/63 40/119 | 17/34 | 0.52 (0.29; 0.94) | -0.16 (-0.29; -0.04) | -6
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Placebo, 52 weeks | HBeAg seroconversion | 52/52 | 7/63 7/56 | 11/12 | 0.89 (0.33; 2.38) | -0.01 (-0.13; 0.10) | -72
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Lamivudine, 100 mg/daily, 52 weeks | HBeAg seroconversion | 52/52 | 7/63 19/119 | 11/16 | 0.70 (0.31; 1.57) | -0.05 (-0.15; 0.05) | -21
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Placebo, 52 weeks | HBeAg seroconversion | 68/68 | 5/63 7/56 | 8/12 | 0.63 (0.21; 1.89) | -0.05 (-0.15; 0.06) | -22
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Lamivudine, 100 mg/daily, 52 weeks | HBeAg seroconversion | 68/68 | 5/63 21/119 | 8/18 | 0.45 (0.18; 1.14) | -0.10 (-0.19; 0.00) | -10
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Placebo, 52 weeks | HBV DNA response: <3pg/ml | 52/52 | 56/63 23/56 | 89/41 | 2.16 (1.56; 3.00) | 0.48 (0.33; 0.63) | 2
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Lamivudine, 100 mg/daily, 52 weeks | HBV DNA response: <3pg/ml | 52/52 | 56/63 102/119 | 89/86 | 1.04 (0.93; 1.16) | 0.03 (-0.07; 0.13) | 32
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Placebo, 52 weeks | Sustained HBV DNA response: no 2 consecutive detectable HBV DNA | 52/52 | 13/63 9/56 | 21/16 | 1.28 (0.59; 2.77) | 0.05 (-0.09; 0.18) | 22
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Lamivudine, 100 mg/daily, 52 weeks | Sustained HBV DNA response: no 2 consecutive detectable HBV DNA | 52/52 | 13/63 60/119 | 21/50 | 0.41 (0.24; 0.69) | -0.30 (-0.43; -0.16) | -3
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Placebo, 52 weeks | HBV DNA undetectable by PCR (<750 genomes/ml) | 24/52 | 26/63 8/56 | 41/14 | 2.89 (1.43; 5.85) | 0.27 (0.12; 0.42) | 4
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Lamivudine, 100 mg/daily, 52 weeks | HBV DNA undetectable by PCR (<750 genomes/ml) | 24/52 | 26/63 34/119 | 41/29 | 1.44 (0.96; 2.17) | 0.13 (-0.02; 0.27) | 8
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Placebo, 52 weeks | HBsAg loss | 52/52 | 4/63 0/56 | 6/0 | 8.02 (0.44; 145.66) | 0.06 (0.00; 0.13) | 16
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Lamivudine, 100 mg/daily, 52 weeks | HBsAg loss | 52/52 | 4/63 2/119 | 6/2 | 3.78 (0.71; 20.06) | 0.05 (-0.02; 0.11) | 21
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Placebo, 52 weeks | HBsAg loss | 68/68 | 3/63 0/56 | 5/0 | 6.23 (0.33; 118.12) | 0.05 (-0.01; 0.11) | 21
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Lamivudine, 100 mg/daily, 52 weeks | HBsAg loss | 68/68 | 3/63 3/119 | 5/3 | 1.89 (0.39; 9.09) | 0.02 (-0.04; 0.08) | 45
Schiff, 2003^47^ lamivudine 100 mg/day for 8 weeks followed by 16 weeks of IFN a-2b, 4 /10 MU 3 times/wee + continued lamivudine to week 24, 52 weeks | Placebo, 52 weeks | Detectable YMDD-variant virus | 52/52 | 0/63 0/56 | | | 0.00 (-0.03; 0.03)
Lamivudine, 100 mg/daily, 52 weeks | Detectable YMDD-variant virus | 52/52 | 0/63 52/119 | 0/44 | 0.02 (0.00; 0.28) | -0.44 (-0.53; -0.35) | -2
Yalcin, 2003^79^ IFN-a-2b, 4/10 MU 3 times per week Lamivudine, 100mg daily, 48 weeks | IFN-a-2b, 4/10 MU 3 times per week, 48 weeks | ALT level normalization | 26/26 | 18/33 5/16 | 55/31 | 1.75 (0.79; 3.85) | 0.23 (-0.05; 0.52) | 4
Yalcin, 2003^79^ IFN-a-2b, 4/10 MU 3 times per week Lamivudine, 100mg daily, 48 weeks | IFN-a-2b, 4/10 MU 3 times per week, 48 weeks | ALT level normalization | 52/52 | 28/33 11/16 | 85/69 | 1.23 (0.86; 1.77) | 0.16 (-0.10; 0.42) | 6
Yalcin, 2003^79^ IFN-a-2b, 4/10 MU 3 times per week Lamivudine, 100mg daily, 48 weeks | IFN-a-2b, 4/10 MU 3 times per week, 48 weeks | 104/104 | 16/33 3/16 | 48/19 | 2.59 (0.88; 7.61) | 0.30 (0.04; 0.55) | 3
Yalcin, 2003^79^ IFN-a-2b, 4/10 MU 3 times per week Lamivudine, 100mg daily, 48 weeks | IFN-a-2b, 4/10 MU 3 times per week, 48 weeks | Sudden flares - intermittent elevations of ALT to 110 times >ULN and >2 from baseline value | 48/48 | 0/33 1/16 | 0/6 | 0.17 (0.01; 3.88) | -0.06 (-0.20; 0.08) | -16
Yalcin, 2003^79^ IFN-a-2b, 4/10 MU 3 times per week Lamivudine, 100mg daily, 48 weeks | IFN-a-2b, 4/10 MU 3 times per week, 48 weeks | Reversion of HBeAg, detection of HBV DNA in serum by PCR, or as an increase in serum ALT level to greater than the ULN (35 IU/L) | 44/44 | 3/33 1/16 | 9/6 | 1.45 (0.16; 12.91) | 0.03 (-0.13; 0.18) | 35
Yalcin, 2003^79^ IFN-a-2b, 4/10 MU 3 times per week Lamivudine, 100mg daily, 48 weeks | IFN-a-2b, 4/10 MU 3 times per week, 48 weeks | Mouth dryness | 48/48 | 25/33 3/16 | 76/19 | 4.04 (1.43; 11.41) | 0.57 (0.33; 0.81) | 2
Yalcin, 2003^79^ IFN-a-2b, 4/10 MU 3 times per week Lamivudine, 100mg daily, 48 weeks | IFN-a-2b, 4/10 MU 3 times per week, 48 weeks | Histological response as improved Knodell HAI score | 48/48 | 26/33 4/16 | 79/25 | 3.15 (1.32; 7.50) | 0.54 (0.28; 0.79) | 2
Yalcin, 2003^79^ IFN-a-2b, 4/10 MU 3 times per week Lamivudine, 100mg daily, 48 weeks | IFN-a-2b, 4/10 MU 3 times per week, 48 weeks | HBeAg seroconversion | 26/26 | 18/33 5/16 | 55/31 | 1.75 (0.79; 3.85) | 0.23 (-0.05; 0.52) | 4
Yalcin, 2003^79^ IFN-a-2b, 4/10 MU 3 times per week Lamivudine, 100mg daily, 48 weeks | IFN-a-2b, 4/10 MU 3 times per week, 48 weeks | HBeAg seroconversion | 52/52 | 22/33 7/16 | 67/44 | 1.52 (0.83; 2.79) | 0.23 (-0.06; 0.52) | 4
Yalcin, 2003^79^ IFN-a-2b, 4/10 MU 3 times per week Lamivudine, 100mg daily, 48 weeks | IFN-a-2b, 4/10 MU 3 times per week, 48 weeks | 104/104 | 18/33 3/16 | 55/19 | 2.91 (1.00; 8.45) | 0.36 (0.10; 0.61) | 3
Yalcin, 2003^79^ IFN-a-2b, 4/10 MU 3 times per week Lamivudine, 100mg daily, 48 weeks | IFN-a-2b, 4/10 MU 3 times per week, 48 weeks | HBV DNA undetectable | 26/26 | 32/33 6/16 | 97/38 | 2.59 (1.37; 4.88) | 0.59 (0.35; 0.84) | 2
Yalcin, 2003^79^ IFN-a-2b, 4/10 MU 3 times per week Lamivudine, 100mg daily, 48 weeks | IFN-a-2b, 4/10 MU 3 times per week, 48 weeks | HBV DNA undetectable | 52/52 | 33/33 9/16 | 100/56 | 1.76 (1.15; 2.70) | 0.44 (0.20; 0.68) | 2
Yalcin, 2003^79^ IFN-a-2b, 4/10 MU 3 times per week Lamivudine, 100mg daily, 48 weeks | IFN-a-2b, 4/10 MU 3 times per week, 48 weeks | 104/104 | 15/33 3/16 | 45/19 | 2.42 (0.82; 7.18) | 0.27 (0.01; 0.52) | 4
HBsAg seroconversion and loss of HBV DNA | 28/28 | 2/33 0/16 | 6/0 | 2.50 (0.13; 49.22) | 0.06 (-0.06; 0.18) | 16
Akarca, 2004^64^ Interferon Alfa, 4 /10 MU three times per week for 24 weeks Lamivudine, 150mg daily, 96 weeks | Lamivudine, 150 mg/day, 96 weeks | Re-elevation of ALT | 96/96 | 2/40 5/40 | 5/12 | 0.40 (0.08; 1.94) | -0.08 (-0.20; 0.05) | -13
Akarca, 2004^64^ Interferon Alfa, 4 /10 MU three times per week for 24 weeks Lamivudine, 150mg daily, 96 weeks | Lamivudine, 150 mg/day, 96 weeks | Flare as elevation in ALT >10 to normal level | 96/96 | 3/40 1/40 | 8/2 | 3.00 (0.33; 27.63) | 0.05 (-0.04; 0.14) | 20
Akarca, 2004^64^ Interferon Alfa, 4 /10 MU three times per week for 24 weeks Lamivudine, 150mg daily, 96 weeks | Lamivudine, 150 mg/day, 96 weeks | HBV DNA negativity and ALT normalization | 96/96 | 32/40 34/40 | 80/85 | 0.94 (0.77; 1.15) | -0.05 (-0.22; 0.12) | -20
Akarca, 2004^64^ Interferon Alfa, 4 /10 MU three times per week for 24 weeks Lamivudine, 150mg daily, 96 weeks | Lamivudine, 150 mg/day, 96 weeks | Reappearance of HBV DNA and increase in ALT | 96/96 | 1/40 3/40 | 2/8 | 0.33 (0.04; 3.07) | -0.05 (-0.14; 0.04) | -20
Akarca, 2004^64^ Interferon Alfa, 4 /10 MU three times per week for 24 weeks Lamivudine, 150mg daily, 96 weeks | Lamivudine, 150 mg/day, 96 weeks | Dose reduction due to adverse effects | 96/96 | 4/40 0/40 | 10/0 | 9.00 (0.50; 161.86) | 0.10 (0.00; 0.20) | 10
Akarca, 2004^64^ Interferon Alfa, 4 /10 MU three times per week for 24 weeks Lamivudine, 150mg daily, 96 weeks | Lamivudine, 150 mg/day, 96 weeks | Thrombocytopenia | 96/96 | 11/40 3/40 | 28/8 | 3.67 (1.11; 12.16) | 0.20 (0.04; 0.36) | 5
Akarca, 2004^64^ Interferon Alfa, 4 /10 MU three times per week for 24 weeks Lamivudine, 150mg daily, 96 weeks | Lamivudine, 150 mg/day, 96 weeks | Undetectable HBV DNA | 24/24 | 34/40 37/40 | 85/92 | 0.92 (0.79; 1.08) | -0.08 (-0.21; 0.06) | -13
Akarca, 2004^64^ Interferon Alfa, 4 /10 MU three times per week for 24 weeks Lamivudine, 150mg daily, 96 weeks | Lamivudine, 150 mg/day, 96 weeks | Undetectable HBV DNA | 96/96 | 39/40 36/40 | 98/90 | 1.08 (0.97; 1.21) | 0.08 (-0.03; 0.18) | 13
HBs Ag negative | 96/96 | 0/40 0/40 | | | 0.00 (-0.05; 0.05)
Jang, 2004^65^ Interferon -a 2b, 2/5 MU 3 times weekly, monotherapy for at least 4 months then combined therapy Lamivudine, 100mg/day, 176 weeks | Lamivudine, 100 mg/daily after Interferon therapy for at least 4 months, 174 weeks | ALT normalization | 200/198 | 37/41 41/42 | 90/97 | 0.92 (0.83; 1.03) | -0.07 (-0.18; 0.03) | -14
Jang, 2004^65^ Interferon -a 2b, 2/5 MU 3 times weekly, monotherapy for at least 4 months then combined therapy Lamivudine, 100mg/day, 176 weeks | Lamivudine, 100 mg/daily after Interferon therapy for at least 4 months, 174 weeks | ALT normalization | 224/222 | 41/41 42/42 | 100/100 | | 0.00 (-0.05; 0.05)
Jang, 2004^65^ Interferon -a 2b, 2/5 MU 3 times weekly, monotherapy for at least 4 months then combined therapy Lamivudine, 100mg/day, 176 weeks | Lamivudine, 100 mg/daily after Interferon therapy for at least 4 months, 174 weeks | 272/270 | 41/41 42/42 | 100/100 | | 0.00 (-0.05; 0.05)
Jang, 2004^65^ Interferon -a 2b, 2/5 MU 3 times weekly, monotherapy for at least 4 months then combined therapy Lamivudine, 100mg/day, 176 weeks | Lamivudine, 100 mg/daily after Interferon therapy for at least 4 months, 174 weeks | Discontinuation due to adverse effects | 368/366 | 3/41 0/42 | 7/0 | 7.17 (0.38; 134.55) | 0.07 (-0.02; 0.16) | 14
Jang, 2004^65^ Interferon -a 2b, 2/5 MU 3 times weekly, monotherapy for at least 4 months then combined therapy Lamivudine, 100mg/day, 176 weeks | Lamivudine, 100 mg/daily after Interferon therapy for at least 4 months, 174 weeks | Severe myalgia | 368/366 | 2/41 0/42 | 5/0 | 5.12 (0.25; 103.48) | 0.05 (-0.03; 0.13) | 20
Jang, 2004^65^ Interferon -a 2b, 2/5 MU 3 times weekly, monotherapy for at least 4 months then combined therapy Lamivudine, 100mg/day, 176 weeks | Lamivudine, 100 mg/daily after Interferon therapy for at least 4 months, 174 weeks | Depression | 368/366 | 1/41 0/42 | 2/0 | 3.07 (0.13; 73.29) | 0.02 (-0.04; 0.09) | 41
Jang, 2004^65^ Interferon -a 2b, 2/5 MU 3 times weekly, monotherapy for at least 4 months then combined therapy Lamivudine, 100mg/day, 176 weeks | Lamivudine, 100 mg/daily after Interferon therapy for at least 4 months, 174 weeks | Undetectable serum HBV-DNA | 200/198 | 40/41 42/42 | 97/100 | 0.98 (0.91; 1.04) | -0.02 (-0.09; 0.04) | -41
Jang, 2004^65^ Interferon -a 2b, 2/5 MU 3 times weekly, monotherapy for at least 4 months then combined therapy Lamivudine, 100mg/day, 176 weeks | Lamivudine, 100 mg/daily after Interferon therapy for at least 4 months, 174 weeks | Undetectable serum HBV-DNA | 224/222 | 41/41 42/42 | 100/100 | | 0.00 (-0.05; 0.05)
Jang, 2004^65^ Interferon -a 2b, 2/5 MU 3 times weekly, monotherapy for at least 4 months then combined therapy Lamivudine, 100mg/day, 176 weeks | Lamivudine, 100 mg/daily after Interferon therapy for at least 4 months, 174 weeks | 272/270 | 41/41 42/42 | 100/100 | | 0.00 (-0.05; 0.05)
Jang, 2004^65^ Interferon -a 2b, 2/5 MU 3 times weekly, monotherapy for at least 4 months then combined therapy Lamivudine, 100mg/day, 176 weeks | Lamivudine, 100 mg/daily after Interferon therapy for at least 4 months, 174 weeks | HBeAg loss | 200/198 | 9/41 9/42 | 22/21 | 1.02 (0.45; 2.32) | 0.01 (-0.17; 0.18) | 191
Jang, 2004^65^ Interferon -a 2b, 2/5 MU 3 times weekly, monotherapy for at least 4 months then combined therapy Lamivudine, 100mg/day, 176 weeks | Lamivudine, 100 mg/daily after Interferon therapy for at least 4 months, 174 weeks | HBeAg loss | 224/222 | 19/41 12/42 | 46/29 | 1.62 (0.91; 2.90) | 0.18 (-0.03; 0.38) | 6
Jang, 2004^65^ Interferon -a 2b, 2/5 MU 3 times weekly, monotherapy for at least 4 months then combined therapy Lamivudine, 100mg/day, 176 weeks | Lamivudine, 100 mg/daily after Interferon therapy for at least 4 months, 174 weeks | HBeAg loss | 272/270 | 25/41 17/42 | 61/41 | 1.51 (0.97; 2.34) | 0.20 (-0.01; 0.42) | 5
Jang, 2004^65^ Interferon -a 2b, 2/5 MU 3 times weekly, monotherapy for at least 4 months then combined therapy Lamivudine, 100mg/day, 176 weeks | Lamivudine, 100 mg/daily after Interferon therapy for at least 4 months, 174 weeks | 320/318 | 27/41 18/42 | 67/44 | 1.54 (1.02; 2.32) | 0.23 (0.02; 0.44) | 4
Jang, 2004^65^ Interferon -a 2b, 2/5 MU 3 times weekly, monotherapy for at least 4 months then combined therapy Lamivudine, 100mg/day, 176 weeks | Lamivudine, 100 mg/daily after Interferon therapy for at least 4 months, 174 weeks | Viral breakthrough as the reappearance of serum HBV-DNA by solution hybridization assay in at least 2 consecutive tests during lamivudine therapy following the disappearance of the serum HBV DNA | 200/198 | 2/41 2/42 | 5/5 | 1.02 (0.15; 6.93) | 0.00 (-0.09; 0.09) | 861
Jang, 2004^65^ Interferon -a 2b, 2/5 MU 3 times weekly, monotherapy for at least 4 months then combined therapy Lamivudine, 100mg/day, 176 weeks | Lamivudine, 100 mg/daily after Interferon therapy for at least 4 months, 174 weeks | Viral breakthrough as the reappearance of serum HBV-DNA by solution hybridization assay in at least 2 consecutive tests during lamivudine therapy following the disappearance of the serum HBV DNA | 224/222 | 2/41 4/42 | 5/10 | 0.51 (0.10; 2.65) | -0.05 (-0.16; 0.06) | -22
Jang, 2004^65^ Interferon -a 2b, 2/5 MU 3 times weekly, monotherapy for at least 4 months then combined therapy Lamivudine, 100mg/day, 176 weeks | Lamivudine, 100 mg/daily after Interferon therapy for at least 4 months, 174 weeks | Viral breakthrough as the reappearance of serum HBV-DNA by solution hybridization assay in at least 2 consecutive tests during lamivudine therapy following the disappearance of the serum HBV DNA | 272/270 | 8/41 23/42 | 20/55 | 0.36 (0.18; 0.70) | -0.35 (-0.55; -0.16) | -3
Jang, 2004^65^ Interferon -a 2b, 2/5 MU 3 times weekly, monotherapy for at least 4 months then combined therapy Lamivudine, 100mg/day, 176 weeks | Lamivudine, 100 mg/daily after Interferon therapy for at least 4 months, 174 weeks | Viral breakthrough as the reappearance of serum HBV-DNA by solution hybridization assay in at least 2 consecutive tests during lamivudine therapy following the disappearance of the serum HBV DNA | 320/318 | 12/41 24/42 | 30/58 | 0.51 (0.30; 0.88) | -0.28 (-0.48; -0.07) | -4
368/366 | 1/41 3/42 | 2/7 | 0.34 (0.04; 3.15) | -0.05 (-0.14; 0.04) | -21
Economou, 2005^63^ IFN-α-2b (Shering-Plough, Athens, Greece), 2/5 MU 3 times per week lamivudine (GSK, Athens, Greece), 100mg/day, 96 weeks | Lamivudine (GSK, Athens, Greece), 100 mg/day, 96 weeks | Normalization of ALT | 24/24 | 14/24 12/26 | 58/46 | 1.26 (0.74; 2.16) | 0.12 (-0.15; 0.40) | 8
Economou, 2005^63^ IFN-α-2b (Shering-Plough, Athens, Greece), 2/5 MU 3 times per week lamivudine (GSK, Athens, Greece), 100mg/day, 96 weeks | Lamivudine (GSK, Athens, Greece), 100 mg/day, 96 weeks | Normalization of ALT | 48/48 | 18/24 21/26 | 75/81 | 0.93 (0.69; 1.25) | -0.06 (-0.29; 0.17) | -17
Economou, 2005^63^ IFN-α-2b (Shering-Plough, Athens, Greece), 2/5 MU 3 times per week lamivudine (GSK, Athens, Greece), 100mg/day, 96 weeks | Lamivudine (GSK, Athens, Greece), 100 mg/day, 96 weeks | Normalization of ALT | 72/72 | 19/24 19/26 | 79/73 | 1.08 (0.79; 1.48) | 0.06 (-0.17; 0.30) | 16
Economou, 2005^63^ IFN-α-2b (Shering-Plough, Athens, Greece), 2/5 MU 3 times per week lamivudine (GSK, Athens, Greece), 100mg/day, 96 weeks | Lamivudine (GSK, Athens, Greece), 100 mg/day, 96 weeks | Normalization of ALT | 96/96 | 19/24 16/26 | 79/62 | 1.29 (0.89; 1.86) | 0.18 (-0.07; 0.42) | 6
Economou, 2005^63^ IFN-α-2b (Shering-Plough, Athens, Greece), 2/5 MU 3 times per week lamivudine (GSK, Athens, Greece), 100mg/day, 96 weeks | Lamivudine (GSK, Athens, Greece), 100 mg/day, 96 weeks | 120/120 | 6/24 5/26 | 25/19 | 1.30 (0.46; 3.71) | 0.06 (-0.17; 0.29) | 17
Economou, 2005^63^ IFN-α-2b (Shering-Plough, Athens, Greece), 2/5 MU 3 times per week lamivudine (GSK, Athens, Greece), 100mg/day, 96 weeks | Lamivudine (GSK, Athens, Greece), 100 mg/day, 96 weeks | Increase of ALT or AST levels to greater than 1.5 times the upper normal limit after an initial biochemical response | 96/96 | 2/24 5/26 | 8/19 | 0.43 (0.09; 2.03) | -0.11 (-0.30; 0.08) | -9
Economou, 2005^63^ IFN-α-2b (Shering-Plough, Athens, Greece), 2/5 MU 3 times per week lamivudine (GSK, Athens, Greece), 100mg/day, 96 weeks | Lamivudine (GSK, Athens, Greece), 100 mg/day, 96 weeks | ALT >10 times the upper normal limit | 96/96 | 0/24 2/26 | 0/8 | 0.22 (0.01; 4.28) | -0.08 (-0.20; 0.05) | -13
Economou, 2005^63^ IFN-α-2b (Shering-Plough, Athens, Greece), 2/5 MU 3 times per week lamivudine (GSK, Athens, Greece), 100mg/day, 96 weeks | Lamivudine (GSK, Athens, Greece), 100 mg/day, 96 weeks | Discontinuation due to adverse effects | 39731 | 3/24 0/26 | 12/0 | 7.56 (0.41; 139.17) | 0.13 (-0.02; 0.27) | 8
Economou, 2005^63^ IFN-α-2b (Shering-Plough, Athens, Greece), 2/5 MU 3 times per week lamivudine (GSK, Athens, Greece), 100mg/day, 96 weeks | Lamivudine (GSK, Athens, Greece), 100 mg/day, 96 weeks | Sustained virological response (undetectable serum HBV DNA concentrations) | 120/120 | 5/24 3/26 | 21/12 | 1.81 (0.48; 6.76) | 0.09 (-0.11; 0.30) | 11
Economou, 2005^63^ IFN-α-2b (Shering-Plough, Athens, Greece), 2/5 MU 3 times per week lamivudine (GSK, Athens, Greece), 100mg/day, 96 weeks | Lamivudine (GSK, Athens, Greece), 100 mg/day, 96 weeks | HBsAg clearance | 120/120 | 0/24 0/26 | | | 0.00 (-0.07; 0.07)
Economou, 2005^63^ IFN-α-2b (Shering-Plough, Athens, Greece), 2/5 MU 3 times per week lamivudine (GSK, Athens, Greece), 100mg/day, 96 weeks | Lamivudine (GSK, Athens, Greece), 100 mg/day, 96 weeks | HBV DNA below detection | 24/24 | 21/24 19/26 | 88/73 | 1.20 (0.91; 1.58) | 0.14 (-0.07; 0.36) | 7
Economou, 2005^63^ IFN-α-2b (Shering-Plough, Athens, Greece), 2/5 MU 3 times per week lamivudine (GSK, Athens, Greece), 100mg/day, 96 weeks | Lamivudine (GSK, Athens, Greece), 100 mg/day, 96 weeks | HBV DNA below detection | 48/48 | 21/24 20/26 | 88/77 | 1.14 (0.88; 1.47) | 0.11 (-0.10; 0.31) | 9
Economou, 2005^63^ IFN-α-2b (Shering-Plough, Athens, Greece), 2/5 MU 3 times per week lamivudine (GSK, Athens, Greece), 100mg/day, 96 weeks | Lamivudine (GSK, Athens, Greece), 100 mg/day, 96 weeks | HBV DNA below detection | 72/72 | 20/24 17/26 | 83/65 | 1.27 (0.91; 1.78) | 0.18 (-0.06; 0.42) | 6
Economou, 2005^63^ IFN-α-2b (Shering-Plough, Athens, Greece), 2/5 MU 3 times per week lamivudine (GSK, Athens, Greece), 100mg/day, 96 weeks | Lamivudine (GSK, Athens, Greece), 100 mg/day, 96 weeks | 96/96 | 18/24 13/26 | 75/50 | 1.50 (0.96; 2.35) | 0.25 (-0.01; 0.51) | 4
Economou, 2005^63^ IFN-α-2b (Shering-Plough, Athens, Greece), 2/5 MU 3 times per week lamivudine (GSK, Athens, Greece), 100mg/day, 96 weeks | Lamivudine (GSK, Athens, Greece), 100 mg/day, 96 weeks | Virologic breakthrough - the reappearance of detectable serum HBV DNA by PCR after an initial virologic response | 96/96 | 3/24 11/26 | 12/42 | 0.30 (0.09; 0.93) | -0.30 (-0.53; -0.07) | -3
YMDD mutations | 96/96 | 2/24 12/26 | 8/46 | 0.18 (0.04; 0.73) | -0.38 (-0.60; -0.16) | -3
Sarin, 2005^69^ IFN-α, 5 MU daily 16 weeks added after the first 8 weeks Lamivudine, 100mg/day, 52 weeks | Lamivudine, 100 mg/day, 52 weeks | Normal ALT | 52/52 | 18/38 15/37 | 47/41 | 1.17 (0.70; 1.95) | 0.07 (-0.16; 0.29) | 15
Sarin, 2005^69^ IFN-α, 5 MU daily 16 weeks added after the first 8 weeks Lamivudine, 100mg/day, 52 weeks | Lamivudine, 100 mg/day, 52 weeks | 76/76 | 15/38 5/37 | 39/14 | 2.92 (1.18; 7.22) | 0.26 (0.07; 0.45) | 4
Sarin, 2005^69^ IFN-α, 5 MU daily 16 weeks added after the first 8 weeks Lamivudine, 100mg/day, 52 weeks | Lamivudine, 100 mg/day, 52 weeks | >10 times rise in ALT | 76/76 | 2/38 0/37 | 5/0 | 4.87 (0.24; 98.18) | 0.05 (-0.03; 0.14) | 19
Sarin, 2005^69^ IFN-α, 5 MU daily 16 weeks added after the first 8 weeks Lamivudine, 100mg/day, 52 weeks | Lamivudine, 100 mg/day, 52 weeks | Withdrawal due to side effects | 39731 | 2/38 0/37 | 5/0 | 4.87 (0.24; 98.18) | 0.05 (-0.03; 0.14) | 19
Sarin, 2005^69^ IFN-α, 5 MU daily 16 weeks added after the first 8 weeks Lamivudine, 100mg/day, 52 weeks | Lamivudine, 100 mg/day, 52 weeks | Influenza-like symptoms | 76/76 | 26/38 7/37 | 68/19 | 3.62 (1.79; 7.29) | 0.50 (0.30; 0.69) | 2
Sarin, 2005^69^ IFN-α, 5 MU daily 16 weeks added after the first 8 weeks Lamivudine, 100mg/day, 52 weeks | Lamivudine, 100 mg/day, 52 weeks | Malaise or fatigue | 76/76 | 4/38 5/37 | 11/14 | 0.78 (0.23; 2.68) | -0.03 (-0.18; 0.12) | -33
Sarin, 2005^69^ IFN-α, 5 MU daily 16 weeks added after the first 8 weeks Lamivudine, 100mg/day, 52 weeks | Lamivudine, 100 mg/day, 52 weeks | Nausea or vomiting | 76/76 | 3/38 2/37 | 8/5 | 1.46 (0.26; 8.25) | 0.02 (-0.09; 0.14) | 40
Sarin, 2005^69^ IFN-α, 5 MU daily 16 weeks added after the first 8 weeks Lamivudine, 100mg/day, 52 weeks | Lamivudine, 100 mg/day, 52 weeks | Headache | 76/76 | 5/38 4/37 | 13/11 | 1.22 (0.35; 4.18) | 0.02 (-0.12; 0.17) | 43
Sarin, 2005^69^ IFN-α, 5 MU daily 16 weeks added after the first 8 weeks Lamivudine, 100mg/day, 52 weeks | Lamivudine, 100 mg/day, 52 weeks | Abdominal discomfort | 76/76 | 4/38 3/37 | 11/8 | 1.30 (0.31; 5.41) | 0.02 (-0.11; 0.16) | 41
Sarin, 2005^69^ IFN-α, 5 MU daily 16 weeks added after the first 8 weeks Lamivudine, 100mg/day, 52 weeks | Lamivudine, 100 mg/day, 52 weeks | Diarrhea | 76/76 | 4/38 3/37 | 11/8 | 1.30 (0.31; 5.41) | 0.02 (-0.11; 0.16) | 41
Sarin, 2005^69^ IFN-α, 5 MU daily 16 weeks added after the first 8 weeks Lamivudine, 100mg/day, 52 weeks | Lamivudine, 100 mg/day, 52 weeks | Reduction of at least 2 points in the HAI score | 52/52 | 14/38 12/37 | 37/32 | 1.14 (0.61; 2.12) | 0.04 (-0.17; 0.26) | 23
Sarin, 2005^69^ IFN-α, 5 MU daily 16 weeks added after the first 8 weeks Lamivudine, 100mg/day, 52 weeks | Lamivudine, 100 mg/day, 52 weeks | increase of at least 2 points in the HAI score | 52/52 | 2/38 2/37 | 5/5 | 0.97 (0.14; 6.56) | 0.00 (-0.10; 0.10) | -703
Sarin, 2005^69^ IFN-α, 5 MU daily 16 weeks added after the first 8 weeks Lamivudine, 100mg/day, 52 weeks | Lamivudine, 100 mg/day, 52 weeks | HBeAg loss | 52/52 | 15/38 14/37 | 39/38 | 1.04 (0.59; 1.85) | 0.02 (-0.20; 0.24) | 61
Sarin, 2005^69^ IFN-α, 5 MU daily 16 weeks added after the first 8 weeks Lamivudine, 100mg/day, 52 weeks | Lamivudine, 100 mg/day, 52 weeks | Undetectable HBV DNA | 52/52 | 16/38 13/37 | 42/35 | 1.20 (0.67; 2.13) | 0.07 (-0.15; 0.29) | 14
Sarin, 2005^69^ IFN-α, 5 MU daily 16 weeks added after the first 8 weeks Lamivudine, 100mg/day, 52 weeks | Lamivudine, 100 mg/day, 52 weeks | HBeAg seroconversion | 52/52 | 10/38 5/37 | 26/14 | 1.95 (0.74; 5.15) | 0.13 (-0.05; 0.31) | 8
Sarin, 2005^69^ IFN-α, 5 MU daily 16 weeks added after the first 8 weeks Lamivudine, 100mg/day, 52 weeks | Lamivudine, 100 mg/day, 52 weeks | HBeAg loss, loss of detectable HBV DNA, and seroconversion to anti-HBe | 52/52 | 10/38 5/37 | 26/14 | 1.95 (0.74; 5.15) | 0.13 (-0.05; 0.31) | 8
Sarin, 2005^69^ IFN-α, 5 MU daily 16 weeks added after the first 8 weeks Lamivudine, 100mg/day, 52 weeks | Lamivudine, 100 mg/day, 52 weeks | 76/76 | 9/38 1/37 | 24/3 | 8.76 (1.17; 65.78) | 0.21 (0.06; 0.35) | 5
Sarin, 2005^69^ IFN-α, 5 MU daily 16 weeks added after the first 8 weeks Lamivudine, 100mg/day, 52 weeks | Lamivudine, 100 mg/day, 52 weeks | Relapse | 76/76 | 1/38 4/37 | 3/11 | 0.24 (0.03; 2.08) | -0.08 (-0.19; 0.03) | -12
Sarin, 2005^69^ IFN-α, 5 MU daily 16 weeks added after the first 8 weeks Lamivudine, 100mg/day, 52 weeks | Lamivudine, 100 mg/day, 52 weeks | HBeAg loss | 76/76 | 17/38 7/37 | 45/19 | 2.36 (1.11; 5.03) | 0.26 (0.06; 0.46) | 4
Sarin, 2005^69^ IFN-α, 5 MU daily 16 weeks added after the first 8 weeks Lamivudine, 100mg/day, 52 weeks | Lamivudine, 100 mg/day, 52 weeks | Undetectable HBV DNA | 76/76 | 15/38 6/37 | 39/16 | 2.43 (1.06; 5.59) | 0.23 (0.04; 0.43) | 4
Sarin, 2005^69^ IFN-α, 5 MU daily 16 weeks added after the first 8 weeks Lamivudine, 100mg/day, 52 weeks | Lamivudine, 100 mg/day, 52 weeks | HBeAg loss, loss of detectable HBV DNA, and seroconversion to anti-HBe | 76/76 | 14/38 4/37 | 37/11 | 3.41 (1.24; 9.40) | 0.26 (0.08; 0.44) | 4
YM552I/VDD-resistant mutants | 52/52 | 6/38 3/37 | 16/8 | 1.95 (0.53; 7.22) | 0.08 (-0.07; 0.22) | 13
Shi, 2006^62^ Lamivudine (Glaxo Wellcome, Suzhou, China), 100mg/day for 20 weeks, then combined with interferon-alfa-2b (Schering-Plough, Shanghai, China), 2/5 MU 3 times per week for 4 weeks and then treated for another 24 weeks with interferon-alpha-2b alone | Lamivudine (Glaxo Wellcome, Suzhou, China), 100 mg/day, 48 weeks | Normalization of ALT | 24/24 | 28/64 72/98 | 44/73 | 0.60 (0.44; 0.81) | -0.30 (-0.45; -0.15) | -3
| Lamivudine (Glaxo Wellcome, Suzhou, China), 100 mg/day, 48 weeks | Normalization of ALT | 48/48 | 38/64 54/98 | 59/55 | 1.08 (0.82; 1.41) | 0.04 (-0.11; 0.20) | 23
| Lamivudine (Glaxo Wellcome, Suzhou, China), 100 mg/day, 48 weeks | 72/72 | 34/64 36/98 | 53/37 | 1.45 (1.02; 2.05) | 0.16 (0.01; 0.32) | 6
| Lamivudine (Glaxo Wellcome, Suzhou, China), 100 mg/day, 48 weeks | Serious adverse events including pyrexia, fatigue, myalgia and headache | 48/48 | 6/64 0/98 | 9/0 | 19.80 (1.13; 345.52) | 0.09 (0.02; 0.17) | 11
| Lamivudine (Glaxo Wellcome, Suzhou, China), 100 mg/day, 48 weeks | HBV DNA <1000 copies/mL | 24/24 | 52/64 76/98 | 81/78 | 1.05 (0.89; 1.23) | 0.04 (-0.09; 0.16) | 27
| Lamivudine (Glaxo Wellcome, Suzhou, China), 100 mg/day, 48 weeks | HBV DNA <1000 copies/mL | 48/48 | 36/64 54/98 | 56/55 | 1.02 (0.77; 1.35) | 0.01 (-0.14; 0.17) | 87
| Lamivudine (Glaxo Wellcome, Suzhou, China), 100 mg/day, 48 weeks | 72/72 | 9/64 18/98 | 14/18 | 0.77 (0.37; 1.60) | -0.04 (-0.16; 0.07) | -23
| Lamivudine (Glaxo Wellcome, Suzhou, China), 100 mg/day, 48 weeks | HBsAg loss or seroconversion | 72/72 | 0/64 0/98 | | | 0.00 (-0.03; 0.03)
| Lamivudine (Glaxo Wellcome, Suzhou, China), 100 mg/day, 48 weeks | YMDD mutants | 24/24 | 2/64 6/98 | 3/6 | 0.51 (0.11; 2.45) | -0.03 (-0.09; 0.03) | -33
| Lamivudine (Glaxo Wellcome, Suzhou, China), 100 mg/day, 48 weeks | 48/48 | 0/64 22/98 | 0/22 | 0.03 (0.00; 0.55) | -0.22 (-0.31; -0.14) | -4
| Lamivudine (Glaxo Wellcome, Suzhou, China), 100 mg/day, 48 weeks | YMDD mutants, YIDD variant | 24/24 | 2/64 4/98 | 3/4 | 0.77 (0.14; 4.06) | -0.01 (-0.07; 0.05) | -105
| Lamivudine (Glaxo Wellcome, Suzhou, China), 100 mg/day, 48 weeks | YMDD mutants, YVDD variants | 24/24 | 0/64 2/98 | 0/2 | 0.30 (0.01; 6.24) | -0.02 (-0.06; 0.02) | -49
| Lamivudine (Glaxo Wellcome, Suzhou, China), 100 mg/day, 48 weeks | YMDD mutants, YIDD variant | 48/48 | 0/64 12/98 | 0/12 | 0.06 (0.00; 1.01) | -0.12 (-0.19; -0.05) | -8
| Lamivudine (Glaxo Wellcome, Suzhou, China), 100 mg/day, 48 weeks | YMDD mutants, YVDD variants | 48/48 | 0/64 8/98 | 0/8 | 0.09 (0.01; 1.53) | -0.08 (-0.14; -0.02) | -12
YMDD mutants, YVDD+YIDD variants | 48/48 | 0/64 2/98 | 0/2 | 0.30 (0.01; 6.24) | -0.02 (-0.06; 0.02) | -49
Scotto, 2006^68^ Alpha-interferon, 3/6 MU 3 times weekly Lamivudine, 100mg/day, 52 weeks | Lamivudine, 100 mg/day, 52 weeks | Response: normal ALT (<40U/L) and undetectable HBV DNA (<5pg/ml) | 39794 | 14/20 13/21 | 70/62 | 1.13 (0.73; 1.76) | 0.08 (-0.21; 0.37) | 12
Lamivudine, 100 mg/day, pre-treatment with lamivudine for 12 weeks, then combined therapy with Interferon, 52 weeks | Response: normal ALT (<40U/L) and undetectable HBV DNA (<5pg/ml) | 39794 | 14/20 13/18 | 70/72 | 0.97 (0.65; 1.45) | -0.02 (-0.31; 0.27) | -45
Scotto, 2006^68^ Pre-treatment with lamivudine for 12 weeks, lamivudine 100 mg/day plus alpha-interferon 6 MU three times weekly, 52 weeks | Lamivudine, 100 mg/day, 52 weeks | Response: normal ALT (<40U/L) and undetectable HBV DNA (<5pg/ml) | 39794 | 13/18 13/21 | 72/62 | 1.17 (0.75; 1.81) | 0.10 (-0.19; 0.40) | 10
Scotto, 2006^68^ Alpha-interferon, 3 /6 MU 3 times weekly Lamivudine, 100mg/day, 52 weeks | Lamivudine, 100 mg/day, 52 weeks | Response: normal ALT (<40U/L) and undetectable HBV DNA (<5pg/ml) | 52/52 | 14/20 13/21 | 70/62 | 1.13 (0.73; 1.76) | 0.08 (-0.21; 0.37) | 12
Lamivudine, 100 mg/day, pre-treatment with lamivudine for 12 weeks, then combined therapy with Interferon, 52 weeks | Response: normal ALT (<40U/L) and undetectable HBV DNA (<5pg/ml) | 52/52 | 14/20 13/18 | 70/72 | 0.97 (0.65; 1.45) | -0.02 (-0.31; 0.27) | -45
Scotto, 2006^68^ Pre-treatment with lamivudine for 12 weeks, lamivudine 100 mg/day plus alpha-interferon 6 MU three times weekly, 52 weeks | Lamivudine, 100 mg/day, 52 weeks | Response: normal ALT (<40U/L) and undetectable HBV DNA (<5pg/ml) | 52/52 | 13/18 13/21 | 72/62 | 1.17 (0.75; 1.81) | 0.10 (-0.19; 0.40) | 10
Scotto, 2006^68^ Alpha-interferon, 3/ 6 MU 3 times weekly Lamivudine, 100mg/day, 52 weeks | Lamivudine, 100 mg/day, 52 weeks | Response: normal ALT (<40U/L) and undetectable HBV DNA (<5pg/ml) | 104/104 | 7/20 7/21 | 35/33 | 1.05 (0.45; 2.46) | 0.02 (-0.27; 0.31) | 60
Lamivudine, 100 mg/day, pre-treatment with lamivudine for 12 weeks, then combined therapy with Interferon, 52 weeks | Response: normal ALT (<40U/L) and undetectable HBV DNA (<5pg/ml) | 104/104 | 7/20 6/18 | 35/33 | 1.05 (0.43; 2.54) | 0.02 (-0.29; 0.32) | 60
Scotto, 2006^68^ Pre-treatment with lamivudine for 12 weeks, lamivudine 100 mg/day plus alpha-interferon 6 MU three times weekly, 52 weeks | Lamivudine, 100 mg/day, 52 weeks | Response: normal ALT (<40U/L) and undetectable HBV DNA (<5pg/ml) | 104/104 | 6/18 7/21 | 33/33 | 1.00 (0.41; 2.44) | 0.00 (-0.30; 0.30)
Scotto, 2006^68^ Alpha-interferon, 3/ 6 MU 3 times weekly Lamivudine, 100mg/day, 52 weeks | Lamivudine, 100 mg/day, 52 weeks | Discontinuation due to adverse effects | 52/52 | 2/20 3/21 | 10/14 | 0.70 (0.13; 3.76) | -0.04 (-0.24; 0.16) | -23
Lamivudine, 100 mg/day, pre-treatment with lamivudine for 12 weeks, then combined therapy with Interferon, 52 weeks | Discontinuation due to adverse effects | 52/52 | 2/20 2/18 | 10/11 | 0.90 (0.14; 5.74) | -0.01 (-0.21; 0.18) | -90
Scotto, 2006^68^ Pre-treatment with lamivudine for 12 weeks, lamivudine 100 mg/day plus alpha-interferon 6 MU three times weekly, 52 weeks | Lamivudine, 100 mg/day, 52 weeks | Discontinuation due to adverse effects | 52/52 | 2/18 3/21 | 11/14 | 0.78 (0.15; 4.15) | -0.03 (-0.24; 0.18) | -32
Scotto, 2006^68^ Alpha-interferon, 3/ 6 MU 3 times weekly Lamivudine, 100mg/day, 52 weeks | Lamivudine, 100 mg/day, 52 weeks | Reduction in HAI score >2 points below baseline | 52/52 | 6/20 5/21 | 30/24 | 1.26 (0.46; 3.48) | 0.06 (-0.21; 0.33) | 16
Lamivudine, 100 mg/day, pre-treatment with lamivudine for 12 weeks, then combined therapy with Interferon, 52 weeks | Reduction in HAI score >2 points below baseline | 52/52 | 6/20 5/18 | 30/28 | 1.08 (0.40; 2.94) | 0.02 (-0.27; 0.31) | 45
Scotto, 2006^68^ Pre-treatment with lamivudine for 12 weeks, lamivudine 100 mg/day plus alpha-interferon 6 MU three times weekly, 52 weeks | Lamivudine, 100 mg/day, 52 weeks | Reduction in HAI score >2 points below baseline | 52/52 | 5/18 5/21 | 28/24 | 1.17 (0.40; 3.39) | 0.04 (-0.24; 0.32) | 25
Scotto, 2006^68^ Alpha-interferon, 3 /6 MU 3 times weekly Lamivudine, 100mg/day, 52 weeks | Lamivudine, 100 mg/day, 52 weeks | Unchanged HAI score | 52/52 | 11/20 13/21 | 55/62 | 0.89 (0.53; 1.49) | -0.07 (-0.37; 0.23) | -14
Lamivudine, 100 mg/day, pre-treatment with lamivudine for 12 weeks, then combined therapy with Interferon, 52 weeks | Unchanged HAI score | 52/52 | 11/20 11/18 | 55/61 | 0.90 (0.52; 1.55) | -0.06 (-0.37; 0.25) | -16
Scotto, 2006^68^ Pre-treatment with lamivudine for 12 weeks, lamivudine 100 mg/day plus alpha-interferon 6 MU three times weekly, 52 weeks | Lamivudine, 100 mg/day, 52 weeks | Unchanged HAI score | 52/52 | 11/18 13/21 | 61/62 | 0.99 (0.60; 1.62) | -0.01 (-0.31; 0.30) | -126
Scotto, 2006^68^ Alpha-interferon, 3/ 6 MU 3 times weekly Lamivudine, 100mg/day, 52 weeks | Lamivudine, 100 mg/day, 52 weeks | Worsening in HAI score | 52/52 | 3/20 3/21 | 15/14 | 1.05 (0.24; 4.61) | 0.01 (-0.21; 0.22) | 140
Lamivudine, 100 mg/day, pre-treatment with lamivudine for 12 weeks, then combined therapy with Interferon, 52 weeks | Worsening in HAI score | 52/52 | 3/20 2/18 | 15/11 | 1.35 (0.25; 7.19) | 0.04 (-0.17; 0.25) | 26
Scotto, 2006^68^ Pre-treatment with lamivudine for 12 weeks, lamivudine 100 mg/day plus alpha-interferon 6 MU three times weekly, 52 weeks | Lamivudine, 100 mg/day, 52 weeks | Worsening in HAI score | 52/52 | 2/18 3/21 | 11/14 | 0.78 (0.15; 4.15) | -0.03 (-0.24; 0.18) | -32
Scotto, 2006^68^ Alpha-interferon, 3 /6 MU 3 times weekly Lamivudine, 100mg/day, 52 weeks | Lamivudine, 100 mg/day, 52 weeks | Undetectable HBV DNA (<6pg/ml) | 52/52 | 14/20 14/21 | 70/67 | 1.05 (0.69; 1.59) | 0.03 (-0.25; 0.32) | 30
Lamivudine, 100 mg/day, pre-treatment with lamivudine for 12 weeks, then combined therapy with Interferon, 52 weeks | Undetectable HBV DNA (<6pg/ml) | 52/52 | 14/20 13/18 | 70/72 | 0.97 (0.65; 1.45) | -0.02 (-0.31; 0.27) | -45
Scotto, 2006^68^ Pre-treatment with lamivudine for 12 weeks, lamivudine 100 mg/day plus alpha-interferon 6 MU three times weekly, 52 weeks | Lamivudine, 100 mg/day, 52 weeks | Undetectable HBV DNA (<6pg/ml) | 52/52 | 13/18 14/21 | 72/67 | 1.08 (0.71; 1.64) | 0.06 (-0.23; 0.34) | 18
Lu, 2007^61^ Interferon alpha 2b, 2/ 5 MU 3 times per week after first 8 months of Lamivudine monotherapy Lamivudine, 100mg/day during the first 8 months, then combination with Interferon, 48 weeks | Interferon alpha 2b, 1 /5 MU 3 times per week, 48 weeks | HBV DNA level ≤1 × 103 and normalization of serum ALT | 48/48 | 0/24 0/12
Lamivudine, 100 mg/day, 48 weeks | HBV DNA level ≤1 × 103 and normalization of serum ALT | 48/48 | 0/24 0/35
Akyuz, 2007^60^ Interferon Alfa 2b, 4/ 10 MU 3 times per week for 24 weeks Lamivudine, 100mg/day, 96 weeks | Lamivudine, 100 mg/day, 96 weeks | Undetected HBV DNA and normalization of ALT | 96/96 | 11/21 16/24 | 52/67 | 0.79 (0.48; 1.29) | -0.14 (-0.43; 0.14) | -7
Akyuz, 2007^60^ Interferon Alfa 2b, 4/ 10 MU 3 times per week for 24 weeks Lamivudine, 100mg/day, 96 weeks | Lamivudine, 100 mg/day, 96 weeks
Akyuz, 2007^60^ Interferon Alfa 2b, 4/ 10 MU 3 times per week for 24 weeks Lamivudine, 100mg/day, 96 weeks | Lamivudine, 100 mg/day, 96 weeks | Undetected HBV DNA and normalization of ALT | 120/120 | 4/21 7/24 | 19/29 | 0.65 (0.22; 1.92) | -0.10 (-0.35; 0.15) | -10
Akyuz, 2007^60^ Interferon Alfa 2b, 4/ 10 MU 3 times per week for 24 weeks Lamivudine, 100mg/day, 96 weeks | Lamivudine, 100 mg/day, 96 weeks
Reappearance of HBV DNA and elevation of ALT (>1.5 times normal level) | 96/96 | 4/21 6/24 | 19/25 | 0.76 (0.25; 2.34) | -0.06 (-0.30; 0.18) | -17
Discontinuation due to adverse events | 96/96 | 3/21 0/24 | 14/0 | 7.95 (0.43; 145.62) | 0.14 (-0.02; 0.31) | 7
YMDD mutations | 96/96 | 10/21 13/24 | 48/54 | 0.88 (0.49; 1.57) | -0.07 (-0.36; 0.23) | -15
Cooksley, 2003^116^ PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 13 /90 mg weekly, 24 weeks | PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 26/ 180 mg weekly, 24 weeks | Normalization of ALT | 48/48 | 21/49 16/46 | 43/35 | 1.23 (0.74; 2.05) | 0.08 (-0.11; 0.28) | 12
PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 39/ 270 mg weekly, 24 weeks | Normalization of ALT | 48/48 | 21/49 15/48 | 43/31 | 1.37 (0.81; 2.33) | 0.12 (-0.07; 0.31) | 9
Cooksley, 2003^116^ PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 26 /180 mg weekly, 24 weeks | PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 39/ 270 mg weekly, 24 weeks | Normalization of ALT | 48/48 | 16/46 15/48 | 35/31 | 1.11 (0.63; 1.98) | 0.04 (-0.15; 0.23) | 28
Cooksley, 2003^116^ PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 13 /90 mg weekly, 24 weeks | PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 26 /180 mg weekly, 24 weeks | HBeAg loss, HBV DNA suppression, and ALT normalization | 48/48 | 13/49 13/46 | 27/28 | 0.94 (0.49; 1.81) | -0.02 (-0.20; 0.16) | -58
PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 39/ 270 mg weekly, 24 weeks | HBeAg loss, HBV DNA suppression, and ALT normalization | 48/48 | 13/49 9/48 | 27/19 | 1.41 (0.67; 3.00) | 0.08 (-0.09; 0.24) | 13
Cooksley, 2003^116^ PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 26 180 mg weekly, 24 weeks | PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 39/ 270 mg weekly, 24 weeks | HBeAg loss, HBV DNA suppression, and ALT normalization | 48/48 | 13/46 9/48 | 28/19 | 1.51 (0.71; 3.18) | 0.10 (-0.08; 0.27) | 11
Cooksley, 2003^116^ PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 13 /90 mg weekly, 24 weeks | PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 26 /180 mg weekly, 24 weeks | Pyrexia | 48/48 | 25/49 27/46 | 52/58 | 0.87 (0.60; 1.25) | -0.08 (-0.28; 0.12) | -13
Cooksley, 2003^116^ PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 13 /90 mg weekly, 24 weeks | PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 26 /180 mg weekly, 24 weeks
Cooksley, 2003^116^ PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 13 /90 mg weekly, 24 weeks | PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 26 /180 mg weekly, 24 weeks | Myalgia | 48/48 | 19/49 17/46 | 38/36 | 1.05 (0.63; 1.76) | 0.02 (-0.18; 0.21) | 55
Cooksley, 2003^116^ PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 13 /90 mg weekly, 24 weeks | PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 26 /180 mg weekly, 24 weeks
Cooksley, 2003^116^ PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 13 /90 mg weekly, 24 weeks | PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 26 /180 mg weekly, 24 weeks | Fatigue | 48/48 | 14/49 10/46 | 29/22 | 1.31 (0.65; 2.66) | 0.07 (-0.11; 0.24) | 15
Cooksley, 2003^116^ PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 13 /90 mg weekly, 24 weeks | PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 26 /180 mg weekly, 24 weeks
Cooksley, 2003^116^ PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 13 /90 mg weekly, 24 weeks | PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 26 /180 mg weekly, 24 weeks | Headache | 48/48 | 23/49 17/46 | 46/38 | 1.27 (0.79; 2.05) | 0.10 (-0.10; 0.30) | 10
Cooksley, 2003^116^ PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 13 /90 mg weekly, 24 weeks | PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 26 /180 mg weekly, 24 weeks
Cooksley, 2003^116^ PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 13 /90 mg weekly, 24 weeks | PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 26 /180 mg weekly, 24 weeks | Alopecia | 48/48 | 8/49 15/46 | 17/33 | 0.50 (0.23; 1.07) | -0.16 (-0.33; 0.01) | -6
Cooksley, 2003^116^ PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 13 /90 mg weekly, 24 weeks | PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 26 /180 mg weekly, 24 weeks
Cooksley, 2003^116^ PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 13 /90 mg weekly, 24 weeks | PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 26 /180 mg weekly, 24 weeks | Anorexia | 48/48 | 4/49 8/46 | 8/18 | 0.47 (0.15; 1.45) | -0.09 (-0.23; 0.04) | -11
Cooksley, 2003^116^ PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 13 /90 mg weekly, 24 weeks
Cooksley, 2003^116^ PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 13 /90 mg weekly, 24 weeks | Insomnia | 48/48 | 8/49 9/46 | 17/20 | 0.83 (0.35; 1.98) | -0.03 (-0.19; 0.12) | -31
Cooksley, 2003^116^ PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 13 /90 mg weekly, 24 weeks
Cooksley, 2003^116^ PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 13 /90 mg weekly, 24 weeks | Dizziness | 48/48 | 9/49 7/46 | 19/16 | 1.21 (0.49; 2.97) | 0.03 (-0.12; 0.18) | 32
Cooksley, 2003^116^ PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 13 /90 mg weekly, 24 weeks
Cooksley, 2003^116^ PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 13 /90 mg weekly, 24 weeks | Diarrhea | 48/48 | 4/49 8/46 | 8/18 | 0.47 (0.15; 1.45) | -0.09 (-0.23; 0.04) | -11
Cooksley, 2003^116^ PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 13 /90 mg weekly, 24 weeks
Cooksley, 2003^116^ PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 13 /90 mg weekly, 24 weeks | Nausea | 48/48 | 5/49 8/46 | 10/18 | 0.59 (0.21; 1.66) | -0.07 (-0.21; 0.07) | -14
Cooksley, 2003^116^ PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 13 /90 mg weekly, 24 weeks
Cooksley, 2003^116^ PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 13 /90 mg weekly, 24 weeks | Upper respiratory infection | 48/48 | 11/49 6/46 | 23/13 | 1.72 (0.69; 4.27) | 0.09 (-0.06; 0.25) | 11
Cooksley, 2003^116^ PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 13 /90 mg weekly, 24 weeks
Cooksley, 2003^116^ PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 13 /90 mg weekly, 24 weeks | Cough | 48/48 | 7/49 3/46 | 15/7 | 2.19 (0.60; 7.97) | 0.08 (-0.04; 0.20) | 13
PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 39/ 270 mg weekly, 24 weeks | Pyrexia | 48/48 | 25/49 34/48 | 52/71 | 0.72 (0.52; 1.00) | -0.20 (-0.39; -0.01) | -5
PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 39/ 270 mg weekly, 24 weeks
PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 39/ 270 mg weekly, 24 weeks | Myalgia | 48/48 | 19/49 22/48 | 38/46 | 0.85 (0.53; 1.35) | -0.07 (-0.27; 0.13) | -14
PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 39/ 270 mg weekly, 24 weeks
PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 39/ 270 mg weekly, 24 weeks | Fatigue | 48/48 | 14/49 13/48 | 29/27 | 1.05 (0.56; 2.00) | 0.01 (-0.16; 0.19) | 67
PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 39/ 270 mg weekly, 24 weeks
PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 39/ 270 mg weekly, 24 weeks | Headache | 48/48 | 23/49 22/48 | 46/46 | 1.02 (0.67; 1.57) | 0.01 (-0.19; 0.21) | 90
PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 39/ 270 mg weekly, 24 weeks
PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 39/ 270 mg weekly, 24 weeks | Alopecia | 48/48 | 8/49 21/48 | 17/44 | 0.37 (0.18; 0.76) | -0.27 (-0.45; -0.10) | -4
PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 39/ 270 mg weekly, 24 weeks
PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 39/ 270 mg weekly, 24 weeks | Anorexia | 48/48 | 4/49 9/48 | 8/19 | 0.44 (0.14; 1.32) | -0.11 (-0.24; 0.03) | -9
Insomnia | 48/48 | 8/49 5/48 | 17/10 | 1.57 (0.55; 4.45) | 0.06 (-0.08; 0.19) | 17
Dizziness | 48/48 | 9/49 7/48 | 19/15 | 1.26 (0.51; 3.11) | 0.04 (-0.11; 0.19) | 26
Diarrhea | 48/48 | 4/49 8/48 | 8/17 | 0.49 (0.16; 1.52) | -0.09 (-0.22; 0.05) | -12
Nausea | 48/48 | 5/49 7/48 | 10/15 | 0.70 (0.24; 2.05) | -0.04 (-0.17; 0.09) | -23
Upper respiratory infection | 48/48 | 11/49 4/48 | 23/8 | 2.69 (0.92; 7.88) | 0.14 (0.00; 0.28) | 7
Cough | 48/48 | 7/49 4/48 | 15/8 | 1.71 (0.54; 5.48) | 0.06 (-0.07; 0.18) | 17
Cooksley, 2003^116^ PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 26 /180 mg weekly, 24 weeks | PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 39 /270 mg weekly, 24 weeks | Pyrexia | 48/48 | 27/46 34/48 | 58/71 | 0.83 (0.61; 1.12) | -0.12 (-0.31; 0.07) | -8
Cooksley, 2003^116^ PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 26 /180 mg weekly, 24 weeks | PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 39 /270 mg weekly, 24 weeks
Cooksley, 2003^116^ PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 26 /180 mg weekly, 24 weeks | PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 39 /270 mg weekly, 24 weeks | Myalgia | 48/48 | 17/46 22/48 | 36/46 | 0.81 (0.50; 1.31) | -0.09 (-0.29; 0.11) | -11
Cooksley, 2003^116^ PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 26 /180 mg weekly, 24 weeks | PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 39 /270 mg weekly, 24 weeks
Cooksley, 2003^116^ PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 26 /180 mg weekly, 24 weeks | PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 39 /270 mg weekly, 24 weeks | Fatigue | 48/48 | 10/46 13/48 | 22/27 | 0.80 (0.39; 1.65) | -0.05 (-0.23; 0.12) | -19
Cooksley, 2003^116^ PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 26 /180 mg weekly, 24 weeks | PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 39 /270 mg weekly, 24 weeks
Cooksley, 2003^116^ PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 26 /180 mg weekly, 24 weeks | PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 39 /270 mg weekly, 24 weeks | Headache | 48/48 | 17/46 22/48 | 38/46 | 0.81 (0.50; 1.31) | -0.09 (-0.29; 0.11) | -11
Cooksley, 2003^116^ PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 26 /180 mg weekly, 24 weeks | PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 39 /270 mg weekly, 24 weeks
Cooksley, 2003^116^ PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 26 /180 mg weekly, 24 weeks | PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 39 /270 mg weekly, 24 weeks | Alopecia | 48/48 | 15/46 21/48 | 33/44 | 0.75 (0.44; 1.26) | -0.11 (-0.31; 0.08) | -9
Cooksley, 2003^116^ PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 26 /180 mg weekly, 24 weeks | PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 39 /270 mg weekly, 24 weeks
Cooksley, 2003^116^ PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 26 /180 mg weekly, 24 weeks | PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 39 /270 mg weekly, 24 weeks | Anorexia | 48/48 | 8/46 9/48 | 18/19 | 0.93 (0.39; 2.20) | -0.01 (-0.17; 0.14) | -74
Insomnia | 48/48 | 9/46 5/48 | 20/10 | 1.88 (0.68; 5.19) | 0.09 (-0.05; 0.24) | 11
Dizziness | 48/48 | 7/46 7/48 | 16/15 | 1.04 (0.40; 2.74) | 0.01 (-0.14; 0.15) | 158
Diarrhea | 48/48 | 8/46 8/48 | 18/17 | 1.04 (0.43; 2.55) | 0.01 (-0.14; 0.16) | 138
Nausea | 48/48 | 8/46 7/48 | 18/15 | 1.19 (0.47; 3.02) | 0.03 (-0.12; 0.18) | 36
Upper respiratory infection | 48/48 | 6/46 4/48 | 13/8 | 1.57 (0.47; 5.19) | 0.05 (-0.08; 0.17) | 21
Cough | 48/48 | 3/46 4/48 | 7/8 | 0.78 (0.19; 3.31) | -0.02 (-0.12; 0.09) | -55
Cooksley, 2003^116^ PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 13/ 90 mg weekly, 24 weeks | PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 26/180 mg weekly, 24 weeks | Loss of HBeAg | 48/48 | 18/49 16/46 | 37/35 | 1.06 (0.62; 1.81) | 0.02 (-0.17; 0.21) | 51
PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 39/270 mg weekly, 24 weeks | Loss of HBeAg | 48/48 | 18/49 14/48 | 37/29 | 1.26 (0.71; 2.24) | 0.08 (-0.11; 0.26) | 13
Cooksley, 2003^116^ PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 26/180 mg weekly, 24 weeks | PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 39/270 mg weekly, 24 weeks | loss of HBeAg | 48/48 | 16/46 14/48 | 35/29 | 1.19 (0.66; 2.16) | 0.06 (-0.13; 0.24) | 18
PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 39 270 mg weekly, 24 weeks | Seroconversion HBeAg | Seroconversion HBeAg | 48/48 | 18/49 15/46 | 37/33 | 1.13 (0.65; 1.96) | 0.04 (-0.15; 0.23) | 24
18/49 13/48 | 37/27 | 1.36 (0.75; 2.45) | 0.10 (-0.09; 0.28) | 10
Cooksley, 2003^116^ PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 26 180 mg weekly, 24 weeks | PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 39/ 270 mg weekly, 24 weeks | Seroconversion HBeAg | 48/48 | 15/46 13/48 | 33/27 | 1.20 (0.65; 2.24) | 0.06 (-0.13; 0.24) | 18
Cooksley, 2003^116^ PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 13 /90 mg weekly, 24 weeks | PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 26/ 180 mg weekly, 24 weeks | Suppression of HBV DNA levels to <500 000 copies/mL | 48/48 | 21/49 18/46 | 43/39 | 1.10 (0.67; 1.78) | 0.04 (-0.16; 0.23) | 27
PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 39/ 270 mg weekly, 24 weeks | Suppression of HBV DNA levels to <500 000 copies/mL | 48/48 | 21/49 13/48 | 43/27 | 1.58 (0.90; 2.79) | 0.16 (-0.03; 0.34) | 6
Cooksley, 2003^116^ PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 26/ 180 mg weekly, 24 weeks | PEGASYS, F. Hoffmann-La Roche Ltd., Basel, Switzerland, 40 kDa, 39/ 270 mg weekly, 24 weeks | Suppression of HBV DNA levels to <500 000 copies/mL | 48/48 | 18/46 13/48 | 39/27 | 1.44 (0.80; 2.60) | 0.12 (-0.07; 0.31) | 8
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100mg/day, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks | Normalization of ALT | 48/48 | 87/181 132/181 | 48/73 | 0.66 (0.55; 0.79) | -0.25 (-0.35; -0.15) | -4
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly Placebo, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks | Normalization of ALT | 48/48 | 67/181 132/181 | 37/73 | 0.51 (0.41; 0.63) | -0.36 (-0.45; -0.26) | -3
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100mg/day, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks | Normalization of ALT | 72/72 | 107/181 80/181 | 59/44 | 1.34 (1.09; 1.64) | 0.15 (0.05; 0.25) | 7
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks | Normalization of ALT | 72/72 | 105/181 80/181 | 58/44 | 1.31 (1.07; 1.61) | 0.14 (0.04; 0.24) | 7
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100mg/day, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks | Normalization of ALT and HBV DNA <20,000 copies/ml | 48/48 | 87/181 125/181 | 48/69 | 0.70 (0.58; 0.83) | -0.21 (-0.31; -0.11) | -5
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly Placebo, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks | Normalization of ALT and HBV DNA <20,000 copies/ml | 48/48 | 63/181 125/181 | 35/69 | 0.50 (0.40; 0.63) | -0.34 (-0.44; -0.25) | -3
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100mg/day, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks | Normalization of ALT and HBV DNA <20,000 copies/ml | 72/72 | 68/181 42/181 | 38/23 | 1.62 (1.17; 2.24) | 0.14 (0.05; 0.24) | 7
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks | Normalization of ALT and HBV DNA <20,000 copies/ml | 72/72 | 63/181 42/181 | 35/23 | 1.50 (1.08; 2.09) | 0.12 (0.02; 0.21) | 9
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100mg/day, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks | Normalization of ALT and HBV DNA <400 copies/ml | 48/48 | 82/181 109/181 | 45/60 | 0.75 (0.62; 0.92) | -0.15 (-0.25; -0.05) | -7
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks | Normalization of ALT and HBV DNA <400 copies/ml | 48/48 | 47/181 109/181 | 26/60 | 0.43 (0.33; 0.57) | -0.34 (-0.44; -0.25) | -3
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100mg/day, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks | Normalization of ALT and HBV DNA <400 copies/ml | 72/72 | 29/181 11/181 | 16/6 | 2.64 (1.36; 5.11) | 0.10 (0.04; 0.16) | 10
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks | Normalization of ALT and HBV DNA <400 copies/ml | 72/72 | 26/181 11/181 | 14/6 | 2.36 (1.20; 4.64) | 0.08 (0.02; 0.14) | 12
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100mg/day, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks | Discontinuation for safety reasons | 48/48 | 7/181 0/181 | 4/0 | 15.00 (0.86; 260.70) | 0.04 (0.01; 0.07) | 26
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100mg/day, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100mg/day, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks | Discontinuation for other reasons | 48/48 | 3/181 4/181 | 2/2 | 0.75 (0.17; 3.30) | -0.01 (-0.03; 0.02) | -181
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100mg/day, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100mg/day, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks | Dose modification | 48/48 | 86/181 0/181 | 48/0 | 173.00 (10.82; 2766.94) | 0.48 (0.40; 0.55) | 2
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100mg/day, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100mg/day, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks | Dose modification due to adverse event | 48/48 | 23/181 0/181 | 13/0 | 47.00 (2.88; 767.96) | 0.13 (0.08; 0.18) | 8
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100mg/day, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100mg/day, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks | Dose modification due to laboratory abnormality | 48/48 | 64/181 0/181 | 35/0 | 129.00 (8.04; 2068.85) | 0.35 (0.28; 0.42) | 3
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100mg/day, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100mg/day, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks | Dose modification due to alanine aminotransferase elevation | 48/48 | 6/181 0/181 | 3/0 | 13.00 (0.74; 229.07) | 0.03 (0.01; 0.06) | 30
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100mg/day, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100mg/day, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks | Dose modification due to neutropenia | 48/48 | 44/181 0/181 | 24/0 | 89.00 (5.52; 1434.24) | 0.24 (0.18; 0.31) | 4
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100mg/day, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100mg/day, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks | Dose modification due to thrombocytopenia | 48/48 | 22/181 0/181 | 12/0 | 45.00 (2.75; 736.24) | 0.12 (0.07; 0.17) | 8
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100mg/day, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100mg/day, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks | ≥1 reported serious adverse event | 48/48 | 12/181 5/181 | 7/3 | 2.40 (0.86; 6.67) | 0.04 (0.00; 0.08) | 26
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100mg/day, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100mg/day, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks | Death | 48/48 | 0/181 0/181 | | | 0.00 (-0.01; 0.01)
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100mg/day, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100mg/day, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks | ≥1 reported adverse event | 48/48 | 155/181 86/181 | 86/48 | 1.80 (1.53; 2.12) | 0.38 (0.29; 0.47) | 3
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100mg/day, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100mg/day, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks | Pyrexia | 48/48 | 98/181 8/181 | 54/4 | 12.25 (6.14; 24.44) | 0.50 (0.42; 0.58) | 2
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100mg/day, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100mg/day, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks | Fatigue | 48/48 | 75/181 33/181 | 41/18 | 2.27 (1.60; 3.24) | 0.23 (0.14; 0.32) | 4
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100mg/day, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100mg/day, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks | Myalgia | 48/48 | 49/181 11/181 | 27/6 | 4.45 (2.39; 8.29) | 0.21 (0.14; 0.28) | 5
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100mg/day, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100mg/day, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks | Headache | 48/48 | 34/181 14/181 | 19/8 | 2.43 (1.35; 4.37) | 0.11 (0.04; 0.18) | 9
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100mg/day, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks
Decreased appetite | 48/48 | 26/181 6/181 | 14/3 | 4.33 (1.83; 10.28) | 0.11 (0.05; 0.17) | 9
Arthralgia | 48/48 | 27/181 6/181 | 15/3 | 4.50 (1.90; 10.64) | 0.12 (0.06; 0.17) | 9
Alopecia | 48/48 | 20/181 1/181 | 11/1 | 20.00 (2.71; 147.45) | 0.10 (0.06; 0.15) | 10
Diarrhea | 48/48 | 10/181 5/181 | 6/3 | 2.00 (0.70; 5.74) | 0.03 (-0.01; 0.07) | 36
Dizziness | 48/48 | 12/181 8/181 | 7/4 | 1.50 (0.63; 3.58) | 0.02 (-0.02; 0.07) | 45
Insomnia | 48/48 | 15/181 5/181 | 8/3 | 3.00 (1.11; 8.08) | 0.06 (0.01; 0.10) | 18
Nausea | 48/48 | 13/181 9/181 | 7/5 | 1.44 (0.63; 3.29) | 0.02 (-0.03; 0.07) | 45
Irritability | 48/48 | 8/181 4/181 | 4/2 | 2.00 (0.61; 6.52) | 0.02 (-0.01; 0.06) | 45
Sore throat | 48/48 | 5/181 8/181 | 3/4 | 0.63 (0.21; 1.87) | -0.02 (-0.05; 0.02) | -60
Rigors | 48/48 | 5/181 0/181 | 3/0 | 11.00 (0.61; 197.48) | 0.03 (0.00; 0.05) | 36
Injection-site reaction | 48/48 | 21/181 0/181 | 12/0 | 43.00 (2.62; 704.52) | 0.12 (0.07; 0.16) | 9
Cough | 48/48 | 5/181 2/181 | 3/1 | 2.50 (0.49; 12.72) | 0.02 (-0.01; 0.04) | 60
Upper respiratory tract infection | 48/48 | 4/181 7/181 | 2/4 | 0.57 (0.17; 1.92) | -0.02 (-0.05; 0.02) | -60
Pruritus | 48/48 | 11/181 4/181 | 6/2 | 2.75 (0.89; 8.48) | 0.04 (0.00; 0.08) | 26
Upper abdominal pain | 48/48 | 12/181 14/181 | 7/8 | 0.86 (0.41; 1.80) | -0.01 (-0.06; 0.04) | -91
Back pain | 48/48 | 11/181 6/181 | 6/3 | 1.83 (0.69; 4.85) | 0.03 (-0.02; 0.07) | 36
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks | Discontinuation for safety reasons | 48/48 | 13/181 0/181 | 7/0 | 27.00 (1.62; 450.80) | 0.07 (0.03; 0.11) | 14
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks | Discontinuation for other reasons | 48/48 | 2/181 4/181 | 1/2 | 0.50 (0.09; 2.70) | -0.01 (-0.04; 0.02) | -91
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks | Dose modification | 48/48 | 83/181 0/181 | 46/0 | 167.00 (10.44; 2671.74) | 0.46 (0.39; 0.53) | 2
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks | Dose modification due to adverse event | 48/48 | 13/181 0/181 | 7/0 | 27.00 (1.62; 450.80) | 0.07 (0.03; 0.11) | 14
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks | Dose modification due to laboratory abnormality | 48/48 | 65/181 0/181 | 36/0 | 131.00 (8.17; 2100.58) | 0.36 (0.29; 0.43) | 3
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks | Dose modification due to alanine aminotransferase elevation | 48/48 | 15/181 0/181 | 8/0 | 31.00 (1.87; 514.22) | 0.08 (0.04; 0.12) | 12
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks | Dose modification due to neutropenia | 48/48 | 30/181 0/181 | 17/0 | 61.00 (3.76; 990.04) | 0.17 (0.11; 0.22) | 6
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks | Dose modification due to thrombocytopenia | 48/48 | 34/181 0/181 | 19/0 | 69.00 (4.26; 1116.95) | 0.19 (0.13; 0.25) | 5
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks | ≥1 reported serious adverse event | 48/48 | 9/181 5/181 | 5/3 | 1.80 (0.62; 5.27) | 0.02 (-0.02; 0.06) | 45
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks | Death | 48/48 | 1/181 0/181 | 1/0 | 3.00 (0.12; 73.16) | 0.01 (-0.01; 0.02) | 181
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks | ≥1 reported adverse event | 48/48 | 155/181 86/181 | 86/48 | 1.80 (1.53; 2.12) | 0.38 (0.29; 0.47) | 3
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks | Pyrexia | 48/48 | 105/181 8/181 | 58/4 | 13.13 (6.59; 26.13) | 0.54 (0.46; 0.61) | 2
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks | Fatigue | 48/48 | 74/181 33/181 | 41/18 | 2.24 (1.57; 3.20) | 0.23 (0.14; 0.32) | 4
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks | Myalgia | 48/48 | 47/181 11/181 | 26/6 | 4.27 (2.29; 7.97) | 0.20 (0.13; 0.27) | 5
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks | Headache | 48/48 | 42/181 14/181 | 23/8 | 3.00 (1.70; 5.30) | 0.15 (0.08; 0.23) | 6
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks | Decreased appetite | 48/48 | 31/181 6/181 | 17/3 | 5.17 (2.21; 12.08) | 0.14 (0.08; 0.20) | 7
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks | Arthralgia | 48/48 | 27/181 6/181 | 15/3 | 4.50 (1.90; 10.64) | 0.12 (0.06; 0.17) | 9
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks
Alopecia | 48/48 | 24/181 1/181 | 13/1 | 24.00 (3.28; 175.53) | 0.13 (0.08; 0.18) | 8
Diarrhea | 48/48 | 20/181 5/181 | 11/3 | 4.00 (1.53; 10.43) | 0.08 (0.03; 0.13) | 12
Dizziness | 48/48 | 15/181 8/181 | 8/4 | 1.88 (0.82; 4.31) | 0.04 (-0.01; 0.09) | 26
Insomnia | 48/48 | 15/181 5/181 | 8/3 | 3.00 (1.11; 8.08) | 0.06 (0.01; 0.10) | 18
Nausea | 48/48 | 14/181 9/181 | 8/5 | 1.56 (0.69; 3.50) | 0.03 (-0.02; 0.08) | 36
Irritability | 48/48 | 12/181 4/181 | 7/2 | 3.00 (0.99; 9.13) | 0.04 (0.00; 0.09) | 23
Sore throat | 48/48 | 11/181 8/181 | 6/4 | 1.38 (0.57; 3.34) | 0.02 (-0.03; 0.06) | 60
Rigors | 48/48 | 10/181 0/181 | 6/0 | 21.00 (1.24; 355.71) | 0.06 (0.02; 0.09) | 18
Injection site reaction | 48/48 | 10/181 0/181 | 6/0 | 21.00 (1.24; 355.71) | 0.06 (0.02; 0.09) | 18
Cough | 48/48 | 10/181 2/181 | 6/1 | 5.00 (1.11; 22.50) | 0.04 (0.01; 0.08) | 23
Upper respiratory tract infection | 48/48 | 9/181 7/181 | 5/4 | 1.29 (0.49; 3.38) | 0.01 (-0.03; 0.05) | 91
Pruritus | 48/48 | 9/181 4/181 | 5/2 | 2.25 (0.71; 7.17) | 0.03 (-0.01; 0.07) | 36
Upper abdominal pain | 48/48 | 9/181 14/181 | 5/8 | 0.64 (0.29; 1.45) | -0.03 (-0.08; 0.02) | -36
Back pain | 48/48 | 4/181 6/181 | 2/3 | 0.67 (0.19; 2.32) | -0.01 (-0.04; 0.02) | -91
Histological response - reduction of at least 2 points in the modified HAI score | 72/72 | 68/181 72/181 | 38/40 | 0.94 (0.73; 1.22) | -0.02 (-0.12; 0.08) | -45
85/181 72/181 | 47/40 | 1.18 (0.93; 1.50) | 0.07 (-0.03; 0.17) | 14
Improved necroinflammatory activity graded from 0 (none) to 18 (severe) | 72/72 | 66/181 57/181 | 36/31 | 1.16 (0.87; 1.54) | 0.05 (-0.05; 0.15) | 20
79/181 57/181 | 44/31 | 1.39 (1.06; 1.82) | 0.12 (0.02; 0.22) | 8
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100mg/day, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks | Worse necroinflammatory activity graded from 0 (none) to 18 (severe) | 72/72 | 23/181 21/181 | 13/12 | 1.10 (0.63; 1.91) | 0.01 (-0.06; 0.08) | 91
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks | Worse necroinflammatory activity graded from 0 (none) to 18 (severe) | 72/72 | 16/181 21/181 | 9/12 | 0.76 (0.41; 1.41) | -0.03 (-0.09; 0.03) | -36
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100mg/day, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks | Improved fibrosis graded from 0 (none) to 18 (severe) | 72/72 | 18/181 22/181 | 10/12 | 0.82 (0.45; 1.47) | -0.02 (-0.09; 0.04) | -45
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks | Improved fibrosis graded from 0 (none) to 18 (severe) | 72/72 | 21/181 22/181 | 12/12 | 0.95 (0.54; 1.67) | -0.01 (-0.07; 0.06) | -181
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100mg/day, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks | Worse fibrosis graded from 0 (none) to 18 (severe) | 72/72 | 15/181 6/181 | 8/3 | 2.50 (0.99; 6.30) | 0.05 (0.00; 0.10) | 20
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks | Worse fibrosis graded from 0 (none) to 18 (severe) | 72/72 | 11/181 6/181 | 6/3 | 1.83 (0.69; 4.85) | 0.03 (-0.02; 0.07) | 36
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100mg/day, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks | HBV DNA <20,000 copies/ml | 48/48 | 164/181 154/181 | 91/85 | 1.06 (0.99; 1.15) | 0.06 (-0.01; 0.12) | 18
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly Placebo, 48 weeks | Lamivudine, 100 mg/day, 48 weeks | HBV DNA <20,000 copies/ml | 48/48 | 144/181 154/181 | 80/85 | 0.94 (0.85; 1.03) | -0.06 (-0.13; 0.02) | -18
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly Lamivudine, 100mg/day, 48 weeks | Lamivudine, 100 mg/day, 48 weeks | HBV DNA <400 copies/ml | 48/48 | 156/181 133/181 | 86/73 | 1.17 (1.06; 1.30) | 0.13 (0.05; 0.21) | 8
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly Placebo, 48 weeks | Lamivudine, 100 mg/day, 48 weeks | HBV DNA <400 copies/ml | 48/48 | 112/181 133/181 | 62/73 | 0.84 (0.73; 0.97) | -0.12 (-0.21; -0.02) | -9
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100mg/day, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks | HBV DNA <20,000 copies/m | 72/72 | 79/181 53/181 | 44/29 | 1.49 (1.13; 1.97) | 0.14 (0.05; 0.24) | 7
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks | HBV DNA <20,000 copies/m | 72/72 | 76/181 53/181 | 42/29 | 1.43 (1.08; 1.90) | 0.13 (0.03; 0.22) | 8
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100mg/day, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks | HBV DNA <400 copies/ml | 72/72 | 35/181 12/181 | 19/7 | 2.92 (1.57; 5.44) | 0.13 (0.06; 0.20) | 8
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26/ 180 mg once weekly, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg/day, 48 weeks | HBV DNA <400 copies/ml | 72/72 | 34/181 12/181 | 19/7 | 2.83 (1.52; 5.29) | 0.12 (0.05; 0.19) | 8
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks | Peginterferon alfa-2a (Pegasys, Roche, 26 180 mg weekly and placebo, 48 weeks | Normalization of ALT | 48/48 | 126/271 105/271 | 46/39 | 1.20 (0.99; 1.46) | 0.08 (-0.01; 0.16) | 13
Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | Normalization of ALT | 48/48 | 126/271 168/272 | 46/62 | 0.75 (0.64; 0.88) | -0.15 (-0.24; -0.07) | -7
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo Placebo, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | Normalization of ALT | 48/48 | 105/271 168/272 | 39/62 | 0.63 (0.53; 0.75) | -0.23 (-0.31; -0.15) | -4
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks | Peginterferon alfa-2a (Pegasys, Roche, 26 180 mg weekly and placebo, 48 weeks | Normalization of ALT | 72/72 | 106/271 111/271 | 39/41 | 0.95 (0.78; 1.17) | -0.02 (-0.10; 0.06) | -54
Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | Normalization of ALT | 72/72 | 106/271 76/272 | 39/28 | 1.40 (1.10; 1.78) | 0.11 (0.03; 0.19) | 9
Lau, 2005^56^ peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo Placebo, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | Normalization of ALT | 72/72 | 111/271 76/272 | 41/28 | 1.47 (1.15; 1.86) | 0.13 (0.05; 0.21) | 8
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks | Peginterferon alfa-2a (Pegasys, Roche, 26 180 mg weekly and placebo, 48 weeks | ALT elevations, defined as a peak value at least 5 times as great as the baseline value | 48/48 | 16/271 14/271 | 6/5 | 1.14 (0.57; 2.30) | 0.01 (-0.03; 0.05) | 135
Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | ALT elevations, defined as a peak value at least 5 times as great as the baseline value | 48/48 | 16/271 12/272 | 6/4 | 1.34 (0.65; 2.78) | 0.01 (-0.02; 0.05) | 67
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo Placebo, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | ALT elevations, defined as a peak value at least 5 times as great as the baseline value | 48/48 | 14/271 12/272 | 5/4 | 1.17 (0.55; 2.49) | 0.01 (-0.03; 0.04) | 133
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks | Peginterferon alfa-2a (Pegasys, Roche, 26 180 mg weekly and placebo, 48 weeks | Deaths (unrelated to hepatitis) | 56/56 | 3/271 0/271 | 1/0 | 7.00 (0.36; 134.87) | 0.01 (0.00; 0.03) | 90
Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | Deaths (unrelated to hepatitis) | 56/56 | 3/271 0/272 | 1/0 | 7.03 (0.36; 135.37) | 0.01 (0.00; 0.03) | 90
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo Placebo, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | Deaths (unrelated to hepatitis) | 56/56 | 0/271 0/272 | | | 0.00 (-0.01; 0.01)
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks | Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo, 48 weeks | HBeAg seroconversion, normalization of ALT, and HBV DNA <100,000 | 48/48 | 42/271 27/271 | 15/10 | 1.56 (0.99; 2.45) | 0.06 (0.00; 0.11) | 18
Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | HBeAg seroconversion, normalization of ALT, and HBV DNA <100,000 | 48/48 | 42/271 50/272 | 15/18 | 0.84 (0.58; 1.23) | -0.03 (-0.09; 0.03) | -35
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo Placebo, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | HBeAg seroconversion, normalization of ALT, and HBV DNA <100,000 | 48/48 | 27/271 50/272 | 10/18 | 0.54 (0.35; 0.84) | -0.08 (-0.14; -0.03) | -12
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks | Peginterferon alfa-2a (Pegasys, Roche, 26 180 mg weekly and placebo, 48 weeks | HBeAg seroconversion, normalization of ALT, and HBV DNA <100,000 | 72/72 | 56/271 62/271 | 21/23 | 0.90 (0.66; 1.24) | -0.02 (-0.09; 0.05) | -45
Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | HBeAg seroconversion, normalization of ALT, and HBV DNA <100,000 | 72/72 | 56/271 28/272 | 21/10 | 2.01 (1.32; 3.06) | 0.10 (0.04; 0.16) | 10
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo Placebo, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | HBeAg seroconversion, normalization of ALT, and HBV DNA <100,000 | 72/72 | 62/271 28/272 | 23/10 | 2.22 (1.47; 3.36) | 0.13 (0.06; 0.19) | 8
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks | Peginterferon alfa-2a (Pegasys, Roche, 26/180 mg weekly and placebo, 48 weeks | Discontinuation due to adverse effects | 48/48 | 12/271 8/271 | 4/3 | 1.50 (0.62; 3.61) | 0.01 (-0.02; 0.05) | 68
Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | Discontinuation due to adverse effects | 48/48 | 12/271 2/272 | 4/1 | 6.02 (1.36; 26.65) | 0.04 (0.01; 0.06) | 27
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo Placebo, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | Discontinuation due to adverse effects | 48/48 | 8/271 2/272 | 3/1 | 4.01 (0.86; 18.73) | 0.02 (0.00; 0.04) | 45
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks | Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo, 48 weeks | Dose modification due to adverse effects | 48/48 | 23/271 20/271 | 8/7 | 1.15 (0.65; 2.04) | 0.01 (-0.03; 0.06) | 90
Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | Dose modification due to adverse effects | 48/48 | 23/271 0/272 | 8/0 | 47.17 (2.88; 772.72) | 0.08 (0.05; 0.12) | 12
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo Placebo, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | Dose modification due to adverse effects | 48/48 | 20/271 0/272 | 7/0 | 41.15 (2.50; 676.96) | 0.07 (0.04; 0.11) | 14
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks | Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo, 48 weeks | Dose modification due to laboratory abnormality: ALT elevation, neutropenia, and thrombocytopenia | 48/48 | 102/271 99/271 | 38/37 | 1.03 (0.83; 1.28) | 0.01 (-0.07; 0.09) | 90
Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | Dose modification due to laboratory abnormality: ALT elevation, neutropenia, and thrombocytopenia | 48/48 | 102/271 0/272 | 38/0 | 205.75 (12.85; 3295.00) | 0.38 (0.32; 0.43) | 3
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo Placebo, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | Dose modification due to laboratory abnormality: ALT elevation, neutropenia, and thrombocytopenia | 48/48 | 99/271 0/272 | 37/0 | 199.73 (12.47; 3199.21) | 0.37 (0.31; 0.42) | 3
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks | Peginterferon alfa-2a (Pegasys, Roche, 26 180 mg weekly and placebo, 48 weeks | ≥1 reported serious adverse event | 56/56 | 16/271 12/271 | 6/4 | 1.33 (0.64; 2.76) | 0.01 (-0.02; 0.05) | 68
Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | ≥1 reported serious adverse event | 56/56 | 16/271 5/272 | 6/2 | 3.21 (1.19; 8.64) | 0.04 (0.01; 0.07) | 25
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo Placebo, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | ≥1 reported serious adverse event | 56/56 | 12/271 5/272 | 4/2 | 2.41 (0.86; 6.74) | 0.03 (0.00; 0.06) | 39
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks | Peginterferon alfa-2a (Pegasys, Roche, 26/180 mg weekly and placebo, 48 weeks | ≥1 reported adverse event | 56/56 | 240/271 240/271 | 89/89 | 1.00 (0.94; 1.06) | 0.00 (-0.05; 0.05)
Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | ≥1 reported adverse event | 56/56 | 240/271 152/272 | 89/56 | 1.58 (1.41; 1.78) | 0.33 (0.26; 0.40) | 3
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/180 mg weekly and placebo Placebo, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | ≥1 reported adverse event | 56/56 | 240/271 152/272 | 89/56 | 1.58 (1.41; 1.78) | 0.33 (0.26; 0.40) | 3
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks | Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo, 48 weeks | Pyrexia | 56/56 | 148/271 133/271 | 55/49 | 1.11 (0.95; 1.31) | 0.06 (-0.03; 0.14) | 18
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks | Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo, 48 weeks
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks | Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo, 48 weeks | Fatigue | 56/56 | 101/271 108/271 | 37/40 | 0.94 (0.76; 1.16) | -0.03 (-0.11; 0.06) | -39
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks | Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo, 48 weeks
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks | Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo, 48 weeks | Headache | 56/56 | 81/271 76/271 | 30/28 | 1.07 (0.82; 1.39) | 0.02 (-0.06; 0.09) | 54
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks | Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo, 48 weeks
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks | Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo, 48 weeks | Myalgia | 56/56 | 77/271 70/271 | 28/26 | 1.10 (0.83; 1.45) | 0.03 (-0.05; 0.10) | 39
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks | Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo, 48 weeks
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks | Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo, 48 weeks | Alopecia | 56/56 | 78/271 55/271 | 29/20 | 1.42 (1.05; 1.92) | 0.08 (0.01; 0.16) | 12
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks | Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo, 48 weeks
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks | Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo, 48 weeks | Decreased appetite | 56/56 | 34/271 40/271 | 13/15 | 0.85 (0.56; 1.30) | -0.02 (-0.08; 0.04) | -45
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks | Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo, 48 weeks
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks | Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo, 48 weeks | Rash | 56/56 | 22/271 27/271 | 8/10 | 0.81 (0.48; 1.39) | -0.02 (-0.07; 0.03) | -54
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks | Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo, 48 weeks
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks | Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo, 48 weeks | Pruritus | 56/56 | 26/271 26/271 | 10/10 | 1.00 (0.60; 1.68) | 0.00 (-0.05; 0.05)
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks | Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo, 48 weeks
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks | Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo, 48 weeks | Dizziness | 56/56 | 32/271 25/271 | 12/9 | 1.28 (0.78; 2.10) | 0.03 (-0.03; 0.08) | 39
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks | Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo, 48 weeks
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks | Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo, 48 weeks | Diarrhea | 56/56 | 26/271 25/271 | 10/9 | 1.04 (0.62; 1.75) | 0.00 (-0.05; 0.05) | 271
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks | Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo, 48 weeks
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks | Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo, 48 weeks | Nausea | 56/56 | 27/271 24/271 | 10/9 | 1.13 (0.67; 1.90) | 0.01 (-0.04; 0.06) | 90
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks | Injection-site reaction | 56/56 | 15/271 24/271 | 6/9 | 0.63 (0.34; 1.17) | -0.03 (-0.08; 0.01) | -30
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks | Arthralgia | 56/56 | 24/271 24/271 | 9/9 | 1.00 (0.58; 1.72) | 0.00 (-0.05; 0.05)
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks | Upper respiratory tract infection | 56/56 | 15/271 21/271 | 6/8 | 0.71 (0.38; 1.36) | -0.02 (-0.06; 0.02) | -45
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks | Insomnia | 56/56 | 23/271 20/271 | 8/7 | 1.15 (0.65; 2.04) | 0.01 (-0.03; 0.06) | 90
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks | Rigors | 56/56 | 27/271 19/271 | 10/7 | 1.42 (0.81; 2.49) | 0.03 (-0.02; 0.08) | 34
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks | Upper abdominal pain | 56/56 | 14/271 19/271 | 5/7 | 0.74 (0.38; 1.44) | -0.02 (-0.06; 0.02) | -54
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks | Sore throat | 56/56 | 21/271 15/271 | 8/6 | 1.40 (0.74; 2.66) | 0.02 (-0.02; 0.06) | 45
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks | Gingival bleeding | 56/56 | 15/271 15/271 | 6/6 | 1.00 (0.50; 2.00) | 0.00 (-0.04; 0.04)
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks | Cough | 56/56 | 19/271 14/271 | 7/5 | 1.36 (0.69; 2.65) | 0.02 (-0.02; 0.06) | 54
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks | Dyspepsia | 56/56 | 6/271 14/271 | 2/5 | 0.43 (0.17; 1.10) | -0.03 (-0.06; 0.00) | -34
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks | Depression | 56/56 | 16/271 13/271 | 6/5 | 1.23 (0.60; 2.51) | 0.01 (-0.03; 0.05) | 90
Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | Pyrexia | 56/56 | 148/271 12/272 | 55/4 | 12.38 (7.04; 21.75) | 0.50 (0.44; 0.57) | 2
Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks
Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | Fatigue | 56/56 | 101/271 37/272 | 37/14 | 2.74 (1.96; 3.84) | 0.24 (0.17; 0.31) | 4
Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks
Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | Headache | 56/56 | 81/271 27/272 | 30/10 | 3.01 (2.01; 4.50) | 0.20 (0.13; 0.26) | 5
Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks
Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | Myalgia | 56/56 | 77/271 8/272 | 28/3 | 9.66 (4.76; 19.62) | 0.25 (0.20; 0.31) | 4
Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks
Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | Alopecia | 56/56 | 78/271 6/272 | 29/2 | 13.05 (5.79; 29.42) | 0.27 (0.21; 0.32) | 4
Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks
Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | Decreased appetite | 56/56 | 34/271 5/272 | 13/2 | 6.83 (2.71; 17.19) | 0.11 (0.06; 0.15) | 9
Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks
Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | Rash | 56/56 | 22/271 10/272 | 8/4 | 2.21 (1.07; 4.57) | 0.04 (0.00; 0.08) | 23
Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks
Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | Pruritus | 56/56 | 26/271 5/272 | 10/2 | 5.22 (2.03; 13.39) | 0.08 (0.04; 0.12) | 13
Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks
Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | Dizziness | 56/56 | 32/271 11/272 | 12/4 | 2.92 (1.50; 5.67) | 0.08 (0.03; 0.12) | 13
Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks
Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | Diarrhea | 56/56 | 26/271 9/272 | 10/3 | 2.90 (1.38; 6.07) | 0.06 (0.02; 0.10) | 16
Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks
Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | Nausea | 56/56 | 27/271 6/272 | 10/2 | 4.52 (1.90; 10.76) | 0.08 (0.04; 0.12) | 13
Injection-site reaction | 56/56 | 15/271 0/272 | 6/0 | 31.11 (1.87; 517.39) | 0.06 (0.03; 0.08) | 18
Arthralgia | 56/56 | 24/271 7/272 | 9/3 | 3.44 (1.51; 7.85) | 0.06 (0.02; 0.10) | 16
Upper respiratory tract infection | 56/56 | 15/271 29/272 | 6/11 | 0.52 (0.28; 0.95) | -0.05 (-0.10; -0.01) | -20
Insomnia | 56/56 | 23/271 10/272 | 8/4 | 2.31 (1.12; 4.76) | 0.05 (0.01; 0.09) | 21
Rigors | 56/56 | 27/271 0/272 | 10/0 | 55.20 (3.38; 900.41) | 0.10 (0.06; 0.14) | 10
Upper abdominal pain | 56/56 | 14/271 20/272 | 5/7 | 0.70 (0.36; 1.36) | -0.02 (-0.06; 0.02) | -46
Sore throat | 56/56 | 21/271 19/272 | 8/7 | 1.11 (0.61; 2.02) | 0.01 (-0.04; 0.05) | 131
Gingival bleeding | 56/56 | 15/271 1/272 | 6/0 | 15.06 (2.00; 113.18) | 0.05 (0.02; 0.08) | 19
Cough | 56/56 | 19/271 10/272 | 7/4 | 1.91 (0.90; 4.03) | 0.03 (0.00; 0.07) | 30
Dyspepsia | 56/56 | 6/271 9/272 | 2/3 | 0.67 (0.24; 1.85) | -0.01 (-0.04; 0.02) | -91
Depression | 56/56 | 16/271 4/272 | 6/1 | 4.01 (1.36; 11.85) | 0.04 (0.01; 0.08) | 23
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo Placebo, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | Pyrexia | 56/56 | 133/271 12/272 | 49/4 | 11.12 (6.31; 19.60) | 0.45 (0.38; 0.51) | 2
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo Placebo, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo Placebo, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | Fatigue | 56/56 | 108/271 37/272 | 40/14 | 2.93 (2.10; 4.09) | 0.26 (0.19; 0.33) | 4
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo Placebo, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo Placebo, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | Headache | 56/56 | 76/271 27/272 | 28/10 | 2.83 (1.88; 4.24) | 0.18 (0.12; 0.25) | 6
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo Placebo, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo Placebo, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | Myalgia | 56/56 | 70/271 8/272 | 26/3 | 8.78 (4.31; 17.90) | 0.23 (0.17; 0.28) | 4
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo Placebo, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo Placebo, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | Alopecia | 56/56 | 55/271 6/272 | 20/2 | 9.20 (4.03; 21.01) | 0.18 (0.13; 0.23) | 6
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo Placebo, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo Placebo, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | Decreased appetite | 56/56 | 40/271 5/272 | 15/2 | 8.03 (3.22; 20.03) | 0.13 (0.08; 0.17) | 8
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo Placebo, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo Placebo, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | Rash | 56/56 | 27/271 10/272 | 10/4 | 2.71 (1.34; 5.49) | 0.06 (0.02; 0.10) | 16
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo Placebo, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo Placebo, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | Pruritus | 56/56 | 26/271 5/272 | 10/2 | 5.22 (2.03; 13.39) | 0.08 (0.04; 0.12) | 13
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo Placebo, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo Placebo, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | Dizziness | 56/56 | 25/271 11/272 | 9/4 | 2.28 (1.15; 4.54) | 0.05 (0.01; 0.09) | 19
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo Placebo, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo Placebo, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | Diarrhea | 56/56 | 25/271 9/272 | 9/3 | 2.79 (1.33; 5.86) | 0.06 (0.02; 0.10) | 17
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo Placebo, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo Placebo, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | Nausea | 56/56 | 24/271 6/272 | 9/2 | 4.01 (1.67; 9.67) | 0.07 (0.03; 0.10) | 15
Injection-site reaction | 56/56 | 24/271 0/272 | 9/0 | 49.18 (3.01; 804.64) | 0.09 (0.05; 0.12) | 11
Arthralgia | 56/56 | 24/271 7/272 | 9/3 | 3.44 (1.51; 7.85) | 0.06 (0.02; 0.10) | 16
Upper respiratory tract infection | 56/56 | 21/271 29/272 | 8/11 | 0.73 (0.43; 1.24) | -0.03 (-0.08; 0.02) | -34
Insomnia | 56/56 | 20/271 10/272 | 7/4 | 2.01 (0.96; 4.21) | 0.04 (0.00; 0.08) | 27
Rigors | 56/56 | 19/271 0/272 | 7/0 | 39.14 (2.38; 645.05) | 0.07 (0.04; 0.10) | 14
Upper abdominal pain | 56/56 | 19/271 20/272 | 7/7 | 0.95 (0.52; 1.75) | 0.00 (-0.05; 0.04) | -293
Sore throat | 56/56 | 15/271 19/272 | 6/7 | 0.79 (0.41; 1.53) | -0.01 (-0.06; 0.03) | -69
Gingival bleeding | 56/56 | 15/271 1/272 | 6/0 | 15.06 (2.00; 113.18) | 0.05 (0.02; 0.08) | 19
Cough | 56/56 | 14/271 10/272 | 5/4 | 1.41 (0.64; 3.11) | 0.01 (-0.02; 0.05) | 67
Dyspepsia | 56/56 | 14/271 9/272 | 5/3 | 1.56 (0.69; 3.55) | 0.02 (-0.02; 0.05) | 54
Depression | 56/56 | 13/271 4/272 | 5/1 | 3.26 (1.08; 9.88) | 0.03 (0.00; 0.06) | 30
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks | Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo, 48 weeks | Histological response - reduction of at least 2 points in the modified HAI score Scores for this index can range from 0 to 24, with inflammation graded from 0 (none) to 18 (severe) and fibrosis graded from 0 | 72/72 | 112/271 102/271 | 41/38 | 1.10 (0.89; 1.35) | 0.04 (-0.05; 0.12) | 27
Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | Histological response - reduction of at least 2 points in the modified HAI score. Scores for this index can range from 0 to 24, with inflammation graded from 0 (none) to 18 (severe) and fibrosis graded from 0 | 72/72 | 112/271 93/272 | 41/34 | 1.21 (0.97; 1.50) | 0.07 (-0.01; 0.15) | 14
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo Placebo, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | Histological response - reduction of at least 2 points in the modified HAI score Scores for this index can range from 0 to 24, with inflammation graded from 0 (none) to 18 (severe) and fibrosis graded from 0 | 72/72 | 102/271 93/272 | 38/34 | 1.10 (0.88; 1.38) | 0.03 (-0.05; 0.12) | 29
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks | Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo, 48 weeks | HBeAg seroconversion: | 48/48 | 64/271 72/271 | 24/27 | 0.89 (0.66; 1.19) | -0.03 (-0.10; 0.04) | -34
Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | HBeAg seroconversion: | 48/48 | 64/271 55/272 | 24/20 | 1.17 (0.85; 1.61) | 0.03 (-0.04; 0.10) | 29
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo Placebo, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | HBeAg seroconversion: | 48/48 | 72/271 55/272 | 27/20 | 1.31 (0.97; 1.79) | 0.06 (-0.01; 0.13) | 16
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks | Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo, 48 weeks | HBeAg seroconversion | 72/72 | 74/271 87/271 | 27/32 | 0.85 (0.66; 1.10) | -0.05 (-0.12; 0.03) | -21
Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | HBeAg seroconversion | 72/72 | 74/271 52/272 | 27/19 | 1.43 (1.05; 1.95) | 0.08 (0.01; 0.15) | 12
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo Placebo, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | HBeAg seroconversion | 72/72 | 87/271 52/272 | 32/19 | 1.68 (1.24; 2.27) | 0.13 (0.06; 0.20) | 8
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks | Peginterferon alfa-2a (Pegasys, Roche, 26/180 mg weekly and placebo, 48 weeks | HBeAg loss | 48/48 | 73/271 81/271 | 27/30 | 0.90 (0.69; 1.18) | -0.03 (-0.11; 0.05) | -34
Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | HBeAg loss | 48/48 | 73/271 59/272 | 27/22 | 1.24 (0.92; 1.67) | 0.05 (-0.02; 0.12) | 19
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo Placebo, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | HBeAg loss | 48/48 | 81/271 59/272 | 30/22 | 1.38 (1.03; 1.84) | 0.08 (0.01; 0.16) | 12
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks | Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo, 48 weeks | HBeAg loss | 72/72 | 77/271 91/271 | 28/34 | 0.85 (0.66; 1.09) | -0.05 (-0.13; 0.03) | -19
Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | HBeAg loss | 72/72 | 77/271 57/272 | 28/21 | 1.36 (1.01; 1.83) | 0.07 (0.00; 0.15) | 13
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo Placebo, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | HBeAg loss | 72/72 | 91/271 57/272 | 34/21 | 1.60 (1.20; 2.13) | 0.13 (0.05; 0.20) | 8
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks | Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo, 48 weeks | HBV DNA <100,000 copies/m | 48/48 | 233/271 142/271 | 86/52 | 1.64 (1.45; 1.86) | 0.34 (0.26; 0.41) | 3
Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | HBV DNA <100,000 copies/m | 48/48 | 233/271 169/272 | 86/62 | 1.38 (1.25; 1.54) | 0.24 (0.17; 0.31) | 4
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo Placebo, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | HBV DNA <100,000 copies/m | 48/48 | 142/271 169/272 | 52/62 | 0.84 (0.73; 0.98) | -0.10 (-0.18; -0.01) | -10
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks | Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo, 48 weeks | HBV DNA <100,000 copies/m | 72/72 | 91/271 86/271 | 34/32 | 1.06 (0.83; 1.35) | 0.02 (-0.06; 0.10) | 54
Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | HBV DNA <100,000 copies/m | 72/72 | 91/271 60/272 | 34/22 | 1.52 (1.15; 2.01) | 0.12 (0.04; 0.19) | 9
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo Placebo, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | HBV DNA <100,000 copies/m | 72/72 | 86/271 60/272 | 32/22 | 1.44 (1.08; 1.91) | 0.10 (0.02; 0.17) | 10
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks | Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo, 48 weeks | HBV DNA <400 copies/ml | 48/48 | 186/271 68/271 | 69/25 | 2.74 (2.19; 3.41) | 0.44 (0.36; 0.51) | 2
Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | HBV DNA <400 copies/ml | 48/48 | 186/271 108/272 | 69/40 | 1.73 (1.46; 2.04) | 0.29 (0.21; 0.37) | 3
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo Placebo, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | HBV DNA <400 copies/ml | 48/48 | 68/271 108/272 | 25/40 | 0.63 (0.49; 0.81) | -0.15 (-0.22; -0.07) | -7
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks | Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo, 48 weeks | HBV DNA <400 copies/ml | 72/72 | 37/271 39/271 | 14/14 | 0.95 (0.63; 1.44) | -0.01 (-0.07; 0.05) | -135
Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | HBV DNA <400 copies/ml | 72/72 | 37/271 14/272 | 14/5 | 2.65 (1.47; 4.79) | 0.09 (0.04; 0.13) | 12
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo Placebo, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | HBV DNA <400 copies/ml | 72/72 | 39/271 14/272 | 14/5 | 2.80 (1.55; 5.03) | 0.09 (0.04; 0.14) | 11
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks | Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo, 48 weeks | YMDD mutations | 48/48 | 9/271 0/271 | 3/0 | 19.00 (1.11; 324.82) | 0.03 (0.01; 0.06) | 30
Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | YMDD mutations | 48/48 | 9/271 69/272 | 3/25 | 0.13 (0.07; 0.26) | -0.22 (-0.28; -0.16) | -5
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo Placebo, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | YMDD mutations | 48/48 | 0/271 69/272 | 0/25 | 0.01 (0.00; 0.12) | -0.25 (-0.31; -0.20) | -4
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks | Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo, 48 weeks | HBeAg seroconversion | 72/72 | 59/271 66/271 | 22/24 | 0.89 (0.66; 1.22) | -0.03 (-0.10; 0.05) | -39
Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | HBeAg seroconversion | 72/72 | 59/271 42/272 | 22/15 | 1.41 (0.99; 2.02) | 0.06 (0.00; 0.13) | 16
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26/ 180 mg weekly and placebo Placebo, 48 weeks | Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | HBeAg seroconversion | 72/72 | 66/271 42/272 | 24/15 | 1.58 (1.11; 2.23) | 0.09 (0.02; 0.16) | 11
Bonino, 2007 ^114^ Peginterferon a-2a (40KD; PEGASYS, Roche, Basel, Switzerland), 26/ 180 mg once weekly Placebo, 100mg/day, 48 weeks | Lamivudine (Epivir-HBV/Zeffix, GlaxoSmithKline, Greenford, UK), 100 mg/day, 48 weeks | Sustained combined response: ALT normalization and an HBV DNA level of 20,000 copies/ml | 72/72 | 34/177 18/181 | 19/10 | 1.93 (1.13; 3.29) | 0.09 (0.02; 0.17) | 11
Janssen, 2005^78^ Peginterferon α-2b, 14/100 microg/week until week 32, then 50mg/week Lamivudine, 100mg/daily, 52 weeks | Peginterferon α-2b + Placebo, 14/ 100 microg/week, 52 weeks | ALT returned to normal | 52/52 | 66/152 46/155 | 43/30 | 1.46 (1.08; 1.98) | 0.14 (0.03; 0.24) | 7
Janssen, 2005^78^ Peginterferon α-2b, 14/100 microg/week until week 32, then 50mg/week Lamivudine, 100mg/daily, 52 weeks | Peginterferon α-2b + Placebo, 14/ 100 microg/week, 52 weeks | 78/78 | 46/152 44/155 | 30/28 | 1.07 (0.75; 1.51) | 0.02 (-0.08; 0.12) | 53
Janssen, 2005^78^ Peginterferon α-2b, 14/100 microg/week until week 32, then 50mg/week Lamivudine, 100mg/daily, 52 weeks | Peginterferon α-2b + Placebo, 14/ 100 microg/week, 52 weeks
Janssen, 2005^78^ Peginterferon α-2b, 14/100 microg/week until week 32, then 50mg/week Lamivudine, 100mg/daily, 52 weeks | Peginterferon α-2b + Placebo, 14/ 100 microg/week, 52 weeks | Flu-like syndrome | 78/78 | 96/152 84/155 | 63/54 | 1.17 (0.96; 1.41) | 0.09 (-0.02; 0.20) | 11
Janssen, 2005^78^ Peginterferon α-2b, 14/100 microg/week until week 32, then 50mg/week Lamivudine, 100mg/daily, 52 weeks | Peginterferon α-2b + Placebo, 14/ 100 microg/week, 52 weeks
Janssen, 2005^78^ Peginterferon α-2b, 14/100 microg/week until week 32, then 50mg/week Lamivudine, 100mg/daily, 52 weeks | Peginterferon α-2b + Placebo, 14/ 100 microg/week, 52 weeks | Headache | 78/78 | 59/152 55/155 | 39/35 | 1.09 (0.82; 1.46) | 0.03 (-0.07; 0.14) | 30
Janssen, 2005^78^ Peginterferon α-2b, 14/100 microg/week until week 32, then 50mg/week Lamivudine, 100mg/daily, 52 weeks | Peginterferon α-2b + Placebo, 14/ 100 microg/week, 52 weeks
Janssen, 2005^78^ Peginterferon α-2b, 14/100 microg/week until week 32, then 50mg/week Lamivudine, 100mg/daily, 52 weeks | Peginterferon α-2b + Placebo, 14/ 100 microg/week, 52 weeks | Fatigue | 78/78 | 54/152 59/155 | 36/38 | 0.93 (0.70; 1.25) | -0.03 (-0.13; 0.08) | -39
Janssen, 2005^78^ Peginterferon α-2b, 14/100 microg/week until week 32, then 50mg/week Lamivudine, 100mg/daily, 52 weeks | Peginterferon α-2b + Placebo, 14/ 100 microg/week, 52 weeks
Janssen, 2005^78^ Peginterferon α-2b, 14/100 microg/week until week 32, then 50mg/week Lamivudine, 100mg/daily, 52 weeks | Peginterferon α-2b + Placebo, 14/ 100 microg/week, 52 weeks | Myalgia | 78/78 | 42/152 41/155 | 28/26 | 1.04 (0.72; 1.51) | 0.01 (-0.09; 0.11) | 85
Janssen, 2005^78^ Peginterferon α-2b, 14/100 microg/week until week 32, then 50mg/week Lamivudine, 100mg/daily, 52 weeks | Peginterferon α-2b + Placebo, 14/ 100 microg/week, 52 weeks
Janssen, 2005^78^ Peginterferon α-2b, 14/100 microg/week until week 32, then 50mg/week Lamivudine, 100mg/daily, 52 weeks | Peginterferon α-2b + Placebo, 14/ 100 microg/week, 52 weeks | Abdominal pain | 78/78 | 25/152 26/155 | 16/17 | 0.98 (0.59; 1.62) | 0.00 (-0.09; 0.08) | -306
Janssen, 2005^78^ Peginterferon α-2b, 14/100 microg/week until week 32, then 50mg/week Lamivudine, 100mg/daily, 52 weeks | Peginterferon α-2b + Placebo, 14/ 100 microg/week, 52 weeks
Janssen, 2005^78^ Peginterferon α-2b, 14/100 microg/week until week 32, then 50mg/week Lamivudine, 100mg/daily, 52 weeks | Peginterferon α-2b + Placebo, 14/ 100 microg/week, 52 weeks | Arthralgia | 78/78 | 20/152 22/155 | 13/14 | 0.93 (0.53; 1.63) | -0.01 (-0.09; 0.07) | -97
Janssen, 2005^78^ Peginterferon α-2b, 14/100 microg/week until week 32, then 50mg/week Lamivudine, 100mg/daily, 52 weeks | Peginterferon α-2b + Placebo, 14/ 100 microg/week, 52 weeks
Janssen, 2005^78^ Peginterferon α-2b, 14/100 microg/week until week 32, then 50mg/week Lamivudine, 100mg/daily, 52 weeks | Peginterferon α-2b + Placebo, 14/ 100 microg/week, 52 weeks | Loss of >10 body weight | 78/78 | 25/152 28/155 | 16/18 | 0.91 (0.56; 1.49) | -0.02 (-0.10; 0.07) | -62
Janssen, 2005^78^ Peginterferon α-2b, 14/100 microg/week until week 32, then 50mg/week Lamivudine, 100mg/daily, 52 weeks | Peginterferon α-2b + Placebo, 14/ 100 microg/week, 52 weeks
Janssen, 2005^78^ Peginterferon α-2b, 14/100 microg/week until week 32, then 50mg/week Lamivudine, 100mg/daily, 52 weeks | Peginterferon α-2b + Placebo, 14/ 100 microg/week, 52 weeks | Anorexia | 78/78 | 21/152 22/155 | 14/14 | 0.97 (0.56; 1.69) | 0.00 (-0.08; 0.07) | -265
Janssen, 2005^78^ Peginterferon α-2b, 14/100 microg/week until week 32, then 50mg/week Lamivudine, 100mg/daily, 52 weeks | Peginterferon α-2b + Placebo, 14/ 100 microg/week, 52 weeks
Janssen, 2005^78^ Peginterferon α-2b, 14/100 microg/week until week 32, then 50mg/week Lamivudine, 100mg/daily, 52 weeks | Peginterferon α-2b + Placebo, 14/ 100 microg/week, 52 weeks | Diarrhea | 78/78 | 14/152 15/155 | 9/10 | 0.95 (0.48; 1.90) | 0.00 (-0.07; 0.06) | -214
Janssen, 2005^78^ Peginterferon α-2b, 14/100 microg/week until week 32, then 50mg/week Lamivudine, 100mg/daily, 52 weeks | Peginterferon α-2b + Placebo, 14/ 100 microg/week, 52 weeks
Janssen, 2005^78^ Peginterferon α-2b, 14/100 microg/week until week 32, then 50mg/week Lamivudine, 100mg/daily, 52 weeks | Peginterferon α-2b + Placebo, 14/ 100 microg/week, 52 weeks | Nausea | 78/78 | 14/152 25/155 | 9/16 | 0.57 (0.31; 1.06) | -0.07 (-0.14; 0.00) | -14
Janssen, 2005^78^ Peginterferon α-2b, 14/100 microg/week until week 32, then 50mg/week Lamivudine, 100mg/daily, 52 weeks | Peginterferon α-2b + Placebo, 14/ 100 microg/week, 52 weeks
Janssen, 2005^78^ Peginterferon α-2b, 14/100 microg/week until week 32, then 50mg/week Lamivudine, 100mg/daily, 52 weeks | Peginterferon α-2b + Placebo, 14/ 100 microg/week, 52 weeks | Local reaction | 78/78 | 38/152 36/155 | 25/23 | 1.08 (0.72; 1.60) | 0.02 (-0.08; 0.11) | 56
Janssen, 2005^78^ Peginterferon α-2b, 14/100 microg/week until week 32, then 50mg/week Lamivudine, 100mg/daily, 52 weeks | Peginterferon α-2b + Placebo, 14/ 100 microg/week, 52 weeks
Janssen, 2005^78^ Peginterferon α-2b, 14/100 microg/week until week 32, then 50mg/week Lamivudine, 100mg/daily, 52 weeks | Peginterferon α-2b + Placebo, 14/ 100 microg/week, 52 weeks | Alopecia | 78/78 | 35/152 26/155 | 23/17 | 1.37 (0.87; 2.16) | 0.06 (-0.03; 0.15) | 16
Janssen, 2005^78^ Peginterferon α-2b, 14/100 microg/week until week 32, then 50mg/week Lamivudine, 100mg/daily, 52 weeks | Peginterferon α-2b + Placebo, 14/ 100 microg/week, 52 weeks
Janssen, 2005^78^ Peginterferon α-2b, 14/100 microg/week until week 32, then 50mg/week Lamivudine, 100mg/daily, 52 weeks | Peginterferon α-2b + Placebo, 14/ 100 microg/week, 52 weeks | Pruritus | 78/78 | 18/152 14/155 | 12/9 | 1.31 (0.68; 2.54) | 0.03 (-0.04; 0.10) | 36
Janssen, 2005^78^ Peginterferon α-2b, 14/100 microg/week until week 32, then 50mg/week Lamivudine, 100mg/daily, 52 weeks | Peginterferon α-2b + Placebo, 14/ 100 microg/week, 52 weeks
Depression | Peginterferon α-2b + Placebo, 14/ 100 microg/week, 52 weeks | 78/78 | 28/152 29/155 | 18/19 | 0.98 (0.62; 1.57) | 0.00 (-0.09; 0.08) | -346
Insomnia | Peginterferon α-2b + Placebo, 14/ 100 microg/week, 52 weeks | 78/78 | 20/152 11/155 | 13/7 | 1.85 (0.92; 3.74) | 0.06 (-0.01; 0.13) | 16
Neutropenia (<1.5*109/L) | Peginterferon α-2b + Placebo, 14/ 100 microg/week, 52 weeks | 78/78 | 34/152 29/155 | 22/19 | 1.20 (0.77; 1.86) | 0.04 (-0.05; 0.13) | 27
Thrombocytopenia (<75*109/L) | Peginterferon α-2b + Placebo, 14/ 100 microg/week, 52 weeks | 78/78 | 14/152 17/155 | 9/11 | 0.84 (0.43; 1.64) | -0.02 (-0.08; 0.05) | -57
Improved fibrosis scores as decrease of at least 1 point for the fibrosis score (range 0–6) | 78/78 | 17/152 13/155 | 11/8 | 1.33 (0.67; 2.65) | 0.03 (-0.04; 0.09) | 36
No improvement in fibrosis scores | 52/52 | 15/152 23/155 | 10/15 | 0.67 (0.36; 1.22) | -0.05 (-0.12; 0.02) | -20
Worsening in fibrosis scores | 52/52 | 20/152 22/155 | 13/14 | 0.93 (0.53; 1.63) | -0.01 (-0.09; 0.07) | -97
Improved inflammatory changes in the liver as decrease of at least 2 points for the necroinflammatory score (range 0–18) | 52/52 | 25/152 31/155 | 16/20 | 0.82 (0.51; 1.33) | -0.04 (-0.12; 0.05) | -28
No Improvement in inflammatory scores | 52/52 | 22/152 21/155 | 14/14 | 1.07 (0.61; 1.86) | 0.01 (-0.07; 0.09) | 108
Worsening in inflammatory scores | 52/52 | 5/152 6/155 | 3/4 | 0.85 (0.26; 2.73) | -0.01 (-0.05; 0.04) | -172
HBeAg loss | 52/52 | 57/152 40/155 | 38/26 | 1.45 (1.04; 2.03) | 0.12 (0.01; 0.22) | 9
HBeAg seroconversion | 52/52 | 33/152 30/155 | 22/19 | 1.12 (0.72; 1.74) | 0.02 (-0.07; 0.11) | 42
HBV DNA <200 000 copies/mL | 52/52 | 96/152 40/155 | 63/26 | 2.45 (1.83; 3.28) | 0.37 (0.27; 0.48) | 3
HBV DNA <400 copies/mL | 52/52 | 43/152 13/155 | 28/8 | 3.37 (1.89; 6.02) | 0.20 (0.12; 0.28) | 5
HBsAg loss | 52/52 | 9/152 7/155 | 6/5 | 1.31 (0.50; 3.43) | 0.01 (-0.04; 0.06) | 71
26 weeks followup | HBsAg seroconversion | 52/52 | 8/152 6/155 | 5/4 | 1.36 (0.48; 3.83) | 0.01 (-0.03; 0.06) | 72
26 weeks followup
26 weeks followup | HBeAg loss | 78/78 | 46/152 49/155 | 30/32 | 0.96 (0.69; 1.34) | -0.01 (-0.12; 0.09) | -74
26 weeks followup
26 weeks followup | HBeAg seroconversion | 78/78 | 38/152 39/155 | 25/25 | 0.99 (0.67; 1.46) | 0.00 (-0.10; 0.10) | -620
26 weeks followup
26 weeks followup | HBV DNA <200 000 copies/mL | 78/78 | 41/152 37/155 | 27/24 | 1.13 (0.77; 1.66) | 0.03 (-0.07; 0.13) | 32
HBV DNA <400 copies/mL | 78/78 | 12/152 9/155 | 8/6 | 1.36 (0.59; 3.13) | 0.02 (-0.04; 0.08) | 48
HBsAg loss | 78/78 | 9/152 9/155 | 6/6 | 1.02 (0.42; 2.50) | 0.00 (-0.05; 0.05) | 873
HBsAg seroconversion | 78/78 | 9/152 7/155 | 6/5 | 1.31 (0.50; 3.43) | 0.01 (-0.04; 0.06) | 71
YMDD mutant | 52/52 | 14/152 0/155 | 9/0 | 29.57 (1.78; 491.31) | 0.09 (0.04; 0.14) | 11
Chan, 2005^59^ Peginterferon alfa-2b (PegIntron; Schering-Plough Corp., Kenilworth, NJ), 14/1.5 g/kg/week for patients with body weight less than 65 kg or 100 g/week for patients with body weight >65 kg8 weeks before the commencement of lamivudine, then a combination of both treatments for 24 weeks Lamivudine (Zeffix; GlaxoSmithKline, Middlesex, UK), 100mg/day, 60 weeks | Lamivudine (Zeffix; GlaxoSmithKline, Middlesex, UK), 100 mg/day, 52 weeks | Severe relapse as ALT level >10 times ULNand HBV DNA level greater than 500,000 copies/mL | 60/52 | 5/50 11/50 | 10/22 | 0.45 (0.17; 1.21) | -0.12 (-0.26; 0.02) | -8
| Lamivudine (Zeffix; GlaxoSmithKline, Middlesex, UK), 100 mg/day, 52 weeks
| Lamivudine (Zeffix; GlaxoSmithKline, Middlesex, UK), 100 mg/day, 52 weeks | Normalization of ALT | 60/52 | 45/50 39/50 | 90/78 | 1.15 (0.97; 1.37) | 0.12 (-0.02; 0.26) | 8
| Lamivudine (Zeffix; GlaxoSmithKline, Middlesex, UK), 100 mg/day, 52 weeks
| Lamivudine (Zeffix; GlaxoSmithKline, Middlesex, UK), 100 mg/day, 52 weeks | Upper respiratory tract symptoms | 60/52 | 37/50 19/50 | 74/38 | 1.95 (1.32; 2.88) | 0.36 (0.18; 0.54) | 3
| Lamivudine (Zeffix; GlaxoSmithKline, Middlesex, UK), 100 mg/day, 52 weeks
| Lamivudine (Zeffix; GlaxoSmithKline, Middlesex, UK), 100 mg/day, 52 weeks | Fever | 60/52 | 36/50 2/50 | 72/4 | 18.00 (4.58; 70.76) | 0.68 (0.54; 0.82) | 1
| Lamivudine (Zeffix; GlaxoSmithKline, Middlesex, UK), 100 mg/day, 52 weeks
| Lamivudine (Zeffix; GlaxoSmithKline, Middlesex, UK), 100 mg/day, 52 weeks | Alopecia | 60/52 | 24/50 2/50 | 48/4 | 12.00 (2.99; 48.09) | 0.44 (0.29; 0.59) | 2
| Lamivudine (Zeffix; GlaxoSmithKline, Middlesex, UK), 100 mg/day, 52 weeks
| Lamivudine (Zeffix; GlaxoSmithKline, Middlesex, UK), 100 mg/day, 52 weeks | Abdominal discomfort | 60/52 | 22/50 13/50 | 44/26 | 1.69 (0.96; 2.97) | 0.18 (0.00; 0.36) | 6
| Lamivudine (Zeffix; GlaxoSmithKline, Middlesex, UK), 100 mg/day, 52 weeks
| Lamivudine (Zeffix; GlaxoSmithKline, Middlesex, UK), 100 mg/day, 52 weeks | Malaise | 60/52 | 22/50 7/50 | 44/14 | 3.14 (1.48; 6.69) | 0.30 (0.13; 0.47) | 3
| Lamivudine (Zeffix; GlaxoSmithKline, Middlesex, UK), 100 mg/day, 52 weeks
| Lamivudine (Zeffix; GlaxoSmithKline, Middlesex, UK), 100 mg/day, 52 weeks | Headache | 60/52 | 21/50 2/50 | 42/4 | 10.50 (2.60; 42.43) | 0.38 (0.23; 0.53) | 3
| Lamivudine (Zeffix; GlaxoSmithKline, Middlesex, UK), 100 mg/day, 52 weeks
| Lamivudine (Zeffix; GlaxoSmithKline, Middlesex, UK), 100 mg/day, 52 weeks | Myalgia | 60/52 | 13/50 2/50 | 26/4 | 6.50 (1.55; 27.33) | 0.22 (0.09; 0.35) | 5
| Lamivudine (Zeffix; GlaxoSmithKline, Middlesex, UK), 100 mg/day, 52 weeks
| Lamivudine (Zeffix; GlaxoSmithKline, Middlesex, UK), 100 mg/day, 52 weeks | Arthralgia | 60/52 | 12/50 2/50 | 24/4 | 6.00 (1.41; 25.44) | 0.20 (0.07; 0.33) | 5
| Lamivudine (Zeffix; GlaxoSmithKline, Middlesex, UK), 100 mg/day, 52 weeks
| Lamivudine (Zeffix; GlaxoSmithKline, Middlesex, UK), 100 mg/day, 52 weeks | Reduced appetite | 60/52 | 12/50 0/50 | 24/0 | 25.00 (1.52; 411.09) | 0.24 (0.12; 0.36) | 4
| Lamivudine (Zeffix; GlaxoSmithKline, Middlesex, UK), 100 mg/day, 52 weeks
| Lamivudine (Zeffix; GlaxoSmithKline, Middlesex, UK), 100 mg/day, 52 weeks | Local erythematous reaction | 60/52 | 12/50 0/50 | 24/0 | 25.00 (1.52; 411.09) | 0.24 (0.12; 0.36) | 4
| Lamivudine (Zeffix; GlaxoSmithKline, Middlesex, UK), 100 mg/day, 52 weeks
| Lamivudine (Zeffix; GlaxoSmithKline, Middlesex, UK), 100 mg/day, 52 weeks | Allergic rashes | 60/52 | 9/50 1/50 | 18/2 | 9.00 (1.18; 68.42) | 0.16 (0.05; 0.27) | 6
| Lamivudine (Zeffix; GlaxoSmithKline, Middlesex, UK), 100 mg/day, 52 weeks
| Lamivudine (Zeffix; GlaxoSmithKline, Middlesex, UK), 100 mg/day, 52 weeks | Dizziness | 60/52 | 8/50 1/50 | 16/2 | 8.00 (1.04; 61.62) | 0.14 (0.03; 0.25) | 7
| Lamivudine (Zeffix; GlaxoSmithKline, Middlesex, UK), 100 mg/day, 52 weeks
| Lamivudine (Zeffix; GlaxoSmithKline, Middlesex, UK), 100 mg/day, 52 weeks | Vomiting or diarrhea | 60/52 | 7/50 3/50 | 14/6 | 2.33 (0.64; 8.51) | 0.08 (-0.04; 0.20) | 13
| Lamivudine (Zeffix; GlaxoSmithKline, Middlesex, UK), 100 mg/day, 52 weeks
| Lamivudine (Zeffix; GlaxoSmithKline, Middlesex, UK), 100 mg/day, 52 weeks | Weight loss (>10) | 60/52 | 7/50 1/50 | 14/2 | 7.00 (0.89; 54.83) | 0.12 (0.02; 0.22) | 8
Increased ALT level | 60/52 | 8/50 12/50 | 16/24 | 0.67 (0.30; 1.49) | -0.08 (-0.24; 0.08) | -13
Decreased phosphate level | 60/52 | 2/50 1/50 | 4/2 | 2.00 (0.19; 21.36) | 0.02 (-0.05; 0.09) | 50
Decreased neutrophil count | 60/52 | 1/50 0/50 | 2/0 | 3.00 (0.13; 71.92) | 0.02 (-0.03; 0.07) | 50
Increased creatine kinase level | 60/52 | 0/50 1/50 | 0/2 | 0.33 (0.01; 7.99) | -0.02 (-0.07; 0.03) | -50
Increased alkaline phosphatase level | 60/52 | 0/50 1/50 | 0/2 | 0.33 (0.01; 7.99) | -0.02 (-0.07; 0.03) | -50
At least 2-point increase in necroinflammatory score | 60/52 | 24/50 26/50 | 48/52 | 0.92 (0.62; 1.37) | -0.04 (-0.24; 0.16) | -25
60/52 | 2/50 4/50 | 4/8 | 0.50 (0.10; 2.61) | -0.04 (-0.13; 0.05) | -25
At least a 2-point increase in fibrosis score | 60/52 | 6/50 4/50 | 12/8 | 1.50 (0.45; 4.99) | 0.04 (-0.08; 0.16) | 25
60/52 | 4/50 2/50 | 8/4 | 2.00 (0.38; 10.43) | 0.04 (-0.05; 0.13) | 25
Sustained virological response as HBeAg seroconversion and HBV DNA level < 500,000 copies/mL | 60/52 | 30/50 14/50 | 60/28 | 2.14 (1.30; 3.53) | 0.32 (0.14; 0.50) | 3
HBV DNA-negative by PCR | 60/52 | 5/50 2/50 | 10/4 | 2.50 (0.51; 12.29) | 0.06 (-0.04; 0.16) | 17
Sustained virological response as HBeAg seroconversion and HBV DNA level < 500,000 copies/mL | 48/48 | 25/50 14/50 | 50/28 | 1.79 (1.06; 3.02) | 0.22 (0.03; 0.41) | 5
24/24 | 18/50 7/50 | 36/14 | 2.57 (1.18; 5.61) | 0.22 (0.06; 0.38) | 5
HBV DNA-negative by PCR | 24/24 | 3/50 2/50 | 6/4 | 1.50 (0.26; 8.60) | 0.02 (-0.07; 0.11) | 50
Virological relapse as either HBV DNA 100,000 copies at any 2 or more occasions or HBeAg reversion | 60/52 | 12/50 7/50 | 24/14 | 1.71 (0.74; 3.99) | 0.10 (-0.05; 0.25) | 10
Lamivudine-resistant mutant | 60/52 | 10/50 19/50 | 20/38 | 0.53 (0.27; 1.02) | -0.18 (-0.35; -0.01) | -6
van Zonneveld, 2005^119^ Peginterferon α-2b, 14 /100 microg/wk until week 32, then 50mg/week Lamivudine, 100mg/daily, 52 weeks | Peginterferon α-2b + Placebo, 14/ 100 microg/week, 52 weeks | Flares defined as an increase in serum ALT to at least 3 times the baseline level | 52/52 | 34/152 37/155 | 22/24 | 0.94 (0.62; 1.41) | -0.02 (-0.11; 0.08) | -67
Reduction in dose of Interferon due to adverse events | 52/52 | 37/152 32/155 | 24/21 | 1.18 (0.78; 1.79) | 0.04 (-0.06; 0.13) | 27
van Zonneveld, 2005^119^ Peginterferon alfa-2b (PegIntron; Schering-Plough Corp., Kenilworth, NJ), 14/ 1.5 g/kg/week for patients with body weight less than 65 kg or 100 g/week for patients with body weight > 65 kg 8 weeks before the commencement of lamivudine, then a combination of both treatments for 24 weeks Lamivudine (Zeffix; GlaxoSmithKline, Middlesex, UK), 100mg/day, 60 weeks | Lamivudine (Zeffix; GlaxoSmithKline, Middlesex, UK), 100 mg/day, 52 weeks | Biochemical relapse as ALT elevation to >2 times ULN | 117/124 | 32/50 38/50 | 64/76 | 0.84 (0.65; 1.09) | -0.12 (-0.30; 0.06) | -8
| Lamivudine (Zeffix; GlaxoSmithKline, Middlesex, UK), 100 mg/day, 52 weeks
| Lamivudine (Zeffix; GlaxoSmithKline, Middlesex, UK), 100 mg/day, 52 weeks | Decompensation as elevated serum bilirubin >50IU/L + ALT elevation >2 times ULN | 117/124 | 2/50 4/50 | 4/8 | 0.50 (0.10; 2.61) | -0.04 (-0.13; 0.05) | -25
| Lamivudine (Zeffix; GlaxoSmithKline, Middlesex, UK), 100 mg/day, 52 weeks
| Lamivudine (Zeffix; GlaxoSmithKline, Middlesex, UK), 100 mg/day, 52 weeks | Elevation of ALT >10 times ULN | 60/52 | 9/50 15/50 | 18/30 | 0.60 (0.29; 1.24) | -0.12 (-0.29; 0.05) | -8
| Lamivudine (Zeffix; GlaxoSmithKline, Middlesex, UK), 100 mg/day, 52 weeks
| Lamivudine (Zeffix; GlaxoSmithKline, Middlesex, UK), 100 mg/day, 52 weeks | Lamivudine treatment for severe post treatment biochemical relapse | 84/76 | 7/50 14/50 | 14/28 | 0.50 (0.22; 1.13) | -0.14 (-0.30; 0.02) | -7
| Lamivudine (Zeffix; GlaxoSmithKline, Middlesex, UK), 100 mg/day, 52 weeks
| Lamivudine (Zeffix; GlaxoSmithKline, Middlesex, UK), 100 mg/day, 52 weeks | Death from acute duodenal ulcer bleeding complicated by shock | 116/116 | 1/50 0/50 | 2/0 | 3.00 (0.13; 71.92) | 0.02 (-0.03; 0.07) | 50
| Lamivudine (Zeffix; GlaxoSmithKline, Middlesex, UK), 100 mg/day, 52 weeks
| Lamivudine (Zeffix; GlaxoSmithKline, Middlesex, UK), 100 mg/day, 52 weeks | Ascites | 117/124 | 0/50 0/50 | | | 0.00 (-0.04; 0.04)
| Lamivudine (Zeffix; GlaxoSmithKline, Middlesex, UK), 100 mg/day, 52 weeks
| Lamivudine (Zeffix; GlaxoSmithKline, Middlesex, UK), 100 mg/day, 52 weeks | Hepatic encephalopathy | 117/124 | 0/50 0/50 | | | 0.00 (-0.04; 0.04)
| Lamivudine (Zeffix; GlaxoSmithKline, Middlesex, UK), 100 mg/day, 52 weeks
| Lamivudine (Zeffix; GlaxoSmithKline, Middlesex, UK), 100 mg/day, 52 weeks | Lost HBeAg | 60/52 | 30/50 13/50 | 60/26 | 2.31 (1.37; 3.88) | 0.34 (0.16; 0.52) | 3
| Lamivudine (Zeffix; GlaxoSmithKline, Middlesex, UK), 100 mg/day, 52 weeks
| Lamivudine (Zeffix; GlaxoSmithKline, Middlesex, UK), 100 mg/day, 52 weeks | HBeAg seroconversion | 60/52 | 29/50 13/50 | 58/26 | 2.23 (1.32; 3.77) | 0.32 (0.14; 0.50) | 3
| Lamivudine (Zeffix; GlaxoSmithKline, Middlesex, UK), 100 mg/day, 52 weeks
Sustained response as sustained HBeAg loss and HBV DNA <100,000 copies/mL | 117/124 | 14/50 4/50 | 28/8 | 3.50 (1.24; 9.90) | 0.20 (0.05; 0.35) | 5
Sustained response as sustained HBeAg loss and HBV DNA <100,000 copies/mL
100/100 | 9/50 3/50 | 18/6 | 3.00 (0.86; 10.43) | 0.12 (-0.01; 0.25) | 8
84/76 | 15/50 5/50 | 30/10 | 3.00 (1.18; 7.63) | 0.20 (0.05; 0.35) | 5
Virological relapse as either HBV DNA 100,000 copies at any 2 or more occasions or HBeAg reversion | 84/76 | 0/50 0/50 | | | 0.00 (-0.04; 0.04)
HBsAg clearance | 52/52 | 1/50 0/50 | 2/0 | 3.00 (0.13; 71.92) | 0.02 (-0.03; 0.07) | 50
Sustained negative HBV DNA by PCR. | 117/124 | 0/50 0/50 | | | 0.00 (-0.04; 0.04)
Negative HBV DNA by PCR | 117/124 | 6/50 2/50 | 12/4 | 3.00 (0.64; 14.16) | 0.08 (-0.03; 0.19) | 13
Elevation of HBV DNA to 100,000 copies/mL | 117/124 | 16/50 9/50 | 32/18 | 1.78 (0.87; 3.64) | 0.14 (-0.03; 0.31) | 7
HBeAg seroconversion | 100/100 | 13/50 8/50 | 26/16 | 1.63 (0.74; 3.58) | 0.10 (-0.06; 0.26) | 10
148/148 | 13/50 15/50 | 26/30 | 0.87 (0.46; 1.63) | -0.04 (-0.22; 0.14) | -25
Flink, 2006^122^ Peginterferon α-2b, 14 /100 microg/week until week 32, then 50mg/week Lamivudine, 100mg/daily, 52 weeks | Peginterferon α-2b + Placebo, 14/ 100 microg/week, 52 weeks | HBeAg clearance | 78/78 | 53/152 56/155 | 35/36 | 0.97 (0.71; 1.30) | -0.01 (-0.12; 0.09) | -79
11/152 11/155 | 7/7 | 1.02 (0.46; 2.28) | 0.00 (-0.06; 0.06) | 714
Zhao, 2007^81^ PegIntron; Schering Corporation, 11 /1.0 mg/kg once per week, 24 weeks | Intron A; Schering Corporation, 1 /3 MIU 3 times per week, 24 weeks | ALT level normalization | 48/48 | 39/115 40/115 | 34/35 | 0.98 (0.68; 1.39) | -0.01 (-0.13; 0.11) | -115
Zhao, 2007^81^ PegIntron; Schering Corporation, 11 /1.0 mg/kg once per week, 24 weeks | Intron A; Schering Corporation, 1 /3 MIU 3 times per week, 24 weeks
Zhao, 2007^81^ PegIntron; Schering Corporation, 11 /1.0 mg/kg once per week, 24 weeks | Intron A; Schering Corporation, 1 /3 MIU 3 times per week, 24 weeks | Sustained combined response: HBeAg negative, HBV DNA <5 log10 copies/mL, and normal ALT level | 48/48 | 20/115 12/115 | 17/10 | 1.67 (0.86; 3.25) | 0.07 (-0.02; 0.16) | 14
Zhao, 2007^81^ PegIntron; Schering Corporation, 11 /1.0 mg/kg once per week, 24 weeks | Intron A; Schering Corporation, 1 /3 MIU 3 times per week, 24 weeks
Zhao, 2007^81^ PegIntron; Schering Corporation, 11 /1.0 mg/kg once per week, 24 weeks | Intron A; Schering Corporation, 1 /3 MIU 3 times per week, 24 weeks | Adverse effects | 48/48 | 86/115 86/115 | 75/75 | 1.00 (0.86; 1.16) | 0.00 (-0.11; 0.11)
Zhao, 2007^81^ PegIntron; Schering Corporation, 11 /1.0 mg/kg once per week, 24 weeks | Intron A; Schering Corporation, 1 /3 MIU 3 times per week, 24 weeks
Zhao, 2007^81^ PegIntron; Schering Corporation, 11 /1.0 mg/kg once per week, 24 weeks | Intron A; Schering Corporation, 1 /3 MIU 3 times per week, 24 weeks | Discontinuation due to drug-related adverse effects | 48/48 | 0/115 4/115 | 0/3 | 0.11 (0.01; 2.04) | -0.03 (-0.07; 0.00) | -29
Zhao, 2007^81^ PegIntron; Schering Corporation, 11 /1.0 mg/kg once per week, 24 weeks | Intron A; Schering Corporation, 1 /3 MIU 3 times per week, 24 weeks
HBV DNA level !5 log 10 copies/mL | 48/48 | 34/115 22/115 | 30/19 | 1.55 (0.97; 2.47) | 0.10 (-0.01; 0.21) | 10
HBV DNA level 3 log copies/mL | 48/48 | 14/115 14/115 | 12/12 | 1.00 (0.50; 2.00) | 0.00 (-0.08; 0.08)
HBeAg loss | 48/48 | 28/115 16/115 | 24/14 | 1.75 (1.00; 3.06) | 0.10 (0.00; 0.21) | 10
HBeAg seroconversion | 48/48 | 25/115 16/115 | 22/14 | 1.56 (0.88; 2.77) | 0.08 (-0.02; 0.18) | 13
HBsAg seroconversion | 48/48 | 0/115 2/115 | 0/2 | 0.20 (0.01; 4.12) | -0.02 (-0.05; 0.01) | -58
(B) Outcomes After Reverse Transcriptase Inhibitors
Author Active Drug, Daily Dose Mg/Day, Combined Active Drug, Daily Dose Mg/Day, Length of Active Treatment (Weeks) | Control Intervention, Daily Dose Mg/Day Length of Control Intervention | Outcome | Length of Treatment/ Followup (Weeks) | Cases/ Randomized Active Control | Rates of Outcomes Active/ Control (%) | Relative Risk (95% CI) | Risk Difference (95% CI) | Number Needed to Treat
Chan, 2007^44^ Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, California) for 24 weeks and then telbivudine(Idenix Pharmaceuticals, Cambridge, MA, for the remaining 28 weeks, 10 mg/day, 52 weeks | Serum ALT normalization | 52/52 | 38/45 39/46 | 85/85 | 1.00 (0.84; 1.19) | 0.00 (-0.15; 0.14) | -296
Chan, 2007^44^ Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, California) for 24 weeks and then telbivudine(Idenix Pharmaceuticals, Cambridge, MA, for the remaining 28 weeks, 10 mg/day, 52 weeks
Chan, 2007^44^ Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, California) for 24 weeks and then telbivudine(Idenix Pharmaceuticals, Cambridge, MA, for the remaining 28 weeks, 10 mg/day, 52 weeks | Adjusted for baseline covariates (baseline HBV DNA level, age, body mass index, sex, and study site) odds ratio of Serum ALT normalization | 52/52 | 0/45 0/46 | | 1.15 (0.31; 4.17)
Chan, 2007^44^ Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, California) for 24 weeks and then telbivudine(Idenix Pharmaceuticals, Cambridge, MA, for the remaining 28 weeks, 10 mg/day, 52 weeks
Chan, 2007^44^ Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, California) for 24 weeks and then telbivudine(Idenix Pharmaceuticals, Cambridge, MA, for the remaining 28 weeks, 10 mg/day, 52 weeks | Total adverse effects | 52/52 | 27/45 31/46 | 61/67 | 0.89 (0.65; 1.22) | -0.07 (-0.27; 0.12) | -14
Chan, 2007^44^ Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, California) for 24 weeks and then telbivudine(Idenix Pharmaceuticals, Cambridge, MA, for the remaining 28 weeks, 10 mg/day, 52 weeks
Chan, 2007^44^ Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, California) for 24 weeks and then telbivudine(Idenix Pharmaceuticals, Cambridge, MA, for the remaining 28 weeks, 10 mg/day, 52 weeks | Upper respiratory tract infection | 52/52 | 5/45 6/46 | 11/13 | 0.85 (0.28; 2.59) | -0.02 (-0.15; 0.11) | -52
Chan, 2007^44^ Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, California) for 24 weeks and then telbivudine(Idenix Pharmaceuticals, Cambridge, MA, for the remaining 28 weeks, 10 mg/day, 52 weeks
Chan, 2007^44^ Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, California) for 24 weeks and then telbivudine(Idenix Pharmaceuticals, Cambridge, MA, for the remaining 28 weeks, 10 mg/day, 52 weeks | Headache | 52/52 | 3/45 6/46 | 7/13 | 0.51 (0.14; 1.92) | -0.06 (-0.19; 0.06) | -16
Chan, 2007^44^ Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, California) for 24 weeks and then telbivudine(Idenix Pharmaceuticals, Cambridge, MA, for the remaining 28 weeks, 10 mg/day, 52 weeks
Chan, 2007^44^ Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, California) for 24 weeks and then telbivudine(Idenix Pharmaceuticals, Cambridge, MA, for the remaining 28 weeks, 10 mg/day, 52 weeks | Back pain | 52/52 | 3/45 3/46 | 7/7 | 1.02 (0.22; 4.80) | 0.00 (-0.10; 0.10) | 690
Chan, 2007^44^ Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, California) for 24 weeks and then telbivudine(Idenix Pharmaceuticals, Cambridge, MA, for the remaining 28 weeks, 10 mg/day, 52 weeks
Chan, 2007^44^ Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, California) for 24 weeks and then telbivudine(Idenix Pharmaceuticals, Cambridge, MA, for the remaining 28 weeks, 10 mg/day, 52 weeks | Diarrhea | 52/52 | 1/45 5/46 | 2/11 | 0.20 (0.02; 1.68) | -0.09 (-0.19; 0.01) | -12
Chan, 2007^44^ Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, California) for 24 weeks and then telbivudine(Idenix Pharmaceuticals, Cambridge, MA, for the remaining 28 weeks, 10 mg/day, 52 weeks
Chan, 2007^44^ Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, California) for 24 weeks and then telbivudine(Idenix Pharmaceuticals, Cambridge, MA, for the remaining 28 weeks, 10 mg/day, 52 weeks | Influenza | 52/52 | 3/45 4/46 | 7/9 | 0.77 (0.18; 3.23) | -0.02 (-0.13; 0.09) | -49
Chan, 2007^44^ Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, California) for 24 weeks and then telbivudine(Idenix Pharmaceuticals, Cambridge, MA, for the remaining 28 weeks, 10 mg/day, 52 weeks
Chan, 2007^44^ Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, California) for 24 weeks and then telbivudine(Idenix Pharmaceuticals, Cambridge, MA, for the remaining 28 weeks, 10 mg/day, 52 weeks | Upper abdominal pain | 52/52 | 2/45 5/46 | 5/11 | 0.41 (0.08; 2.00) | -0.06 (-0.17; 0.04) | -16
Chan, 2007^44^ Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, California) for 24 weeks and then telbivudine(Idenix Pharmaceuticals, Cambridge, MA, for the remaining 28 weeks, 10 mg/day, 52 weeks
Chan, 2007^44^ Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, California) for 24 weeks and then telbivudine(Idenix Pharmaceuticals, Cambridge, MA, for the remaining 28 weeks, 10 mg/day, 52 weeks | Nasopharyngitis | 52/52 | 5/45 2/46 | 11/4 | 2.56 (0.52; 12.50) | 0.07 (-0.04; 0.18) | 15
Chan, 2007^44^ Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, California) for 24 weeks and then telbivudine(Idenix Pharmaceuticals, Cambridge, MA, for the remaining 28 weeks, 10 mg/day, 52 weeks
Chan, 2007^44^ Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, California) for 24 weeks and then telbivudine(Idenix Pharmaceuticals, Cambridge, MA, for the remaining 28 weeks, 10 mg/day, 52 weeks | Cough | 52/52 | 0/45 6/46 | 0/13 | 0.08 (0.00; 1.36) | -0.13 (-0.23; -0.03) | -8
Chan, 2007^44^ Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, California) for 24 weeks and then telbivudine(Idenix Pharmaceuticals, Cambridge, MA, for the remaining 28 weeks, 10 mg/day, 52 weeks
Chan, 2007^44^ Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, California) for 24 weeks and then telbivudine(Idenix Pharmaceuticals, Cambridge, MA, for the remaining 28 weeks, 10 mg/day, 52 weeks | Arthralgia | 52/52 | 2/45 2/46 | 5/4 | 1.02 (0.15; 6.95) | 0.00 (-0.08; 0.09) | 1035
Chan, 2007^44^ Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, California) for 24 weeks and then telbivudine(Idenix Pharmaceuticals, Cambridge, MA, for the remaining 28 weeks, 10 mg/day, 52 weeks
Chan, 2007^44^ Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, California) for 24 weeks and then telbivudine(Idenix Pharmaceuticals, Cambridge, MA, for the remaining 28 weeks, 10 mg/day, 52 weeks | Fatigue | 52/52 | 0/45 4/46 | 0/9 | 0.11 (0.01; 2.05) | -0.09 (-0.18; 0.00) | -12
Chan, 2007^44^ Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, California) for 24 weeks and then telbivudine(Idenix Pharmaceuticals, Cambridge, MA, for the remaining 28 weeks, 10 mg/day, 52 weeks
Chan, 2007^44^ Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, California) for 24 weeks and then telbivudine(Idenix Pharmaceuticals, Cambridge, MA, for the remaining 28 weeks, 10 mg/day, 52 weeks | Dizziness | 52/52 | 0/45 4/46 | 0/9 | 0.11 (0.01; 2.05) | -0.09 (-0.18; 0.00) | -12
Chan, 2007^44^ Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, California) for 24 weeks and then telbivudine(Idenix Pharmaceuticals, Cambridge, MA, for the remaining 28 weeks, 10 mg/day, 52 weeks
Chan, 2007^44^ Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, California) for 24 weeks and then telbivudine(Idenix Pharmaceuticals, Cambridge, MA, for the remaining 28 weeks, 10 mg/day, 52 weeks | Malaise | 52/52 | 0/45 2/46 | 0/4 | 0.20 (0.01; 4.14) | -0.04 (-0.11; 0.03) | -23
Chan, 2007^44^ Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, California) for 24 weeks and then telbivudine(Idenix Pharmaceuticals, Cambridge, MA, for the remaining 28 weeks, 10 mg/day, 52 weeks
Chan, 2007^44^ Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, California) for 24 weeks and then telbivudine(Idenix Pharmaceuticals, Cambridge, MA, for the remaining 28 weeks, 10 mg/day, 52 weeks | Nausea | 52/52 | 2/45 1/46 | 5/2 | 2.04 (0.19; 21.76) | 0.02 (-0.05; 0.10) | 44
Chan, 2007^44^ Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, California) for 24 weeks and then telbivudine(Idenix Pharmaceuticals, Cambridge, MA, for the remaining 28 weeks, 10 mg/day, 52 weeks
Chan, 2007^44^ Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, California) for 24 weeks and then telbivudine(Idenix Pharmaceuticals, Cambridge, MA, for the remaining 28 weeks, 10 mg/day, 52 weeks | Pharyngolaryngeal pain | 52/52 | 3/45 1/46 | 7/2 | 3.07 (0.33; 28.39) | 0.04 (-0.04; 0.13) | 22
Chan, 2007^44^ Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, California) for 24 weeks and then telbivudine(Idenix Pharmaceuticals, Cambridge, MA, for the remaining 28 weeks, 10 mg/day, 52 weeks
Abdominal pain | 52/52 | 1/45 0/46 | 2/0 | 3.07 (0.13; 73.32) | 0.02 (-0.04; 0.08) | 45
Epigastric discomfort | 52/52 | 0/45 1/46 | 0/2 | 0.34 (0.01; 8.15) | -0.02 (-0.08; 0.04) | -46
Gastritis | 52/52 | 0/45 0/46 | | | 0.00 (-0.04; 0.04)
Hepatic steatosis | 52/52 | 1/45 0/46 | 2/0 | 3.07 (0.13; 73.32) | 0.02 (-0.04; 0.08) | 45
Mouth ulceration | 52/52 | 2/45 1/46 | 5/2 | 2.04 (0.19; 21.76) | 0.02 (-0.05; 0.10) | 44
Myalgia | 52/52 | 0/45 2/46 | 0/4 | 0.20 (0.01; 4.14) | -0.04 (-0.11; 0.03) | -23
Toothache | 52/52 | 1/45 0/46 | 2/0 | 3.07 (0.13; 73.32) | 0.02 (-0.04; 0.08) | 45
Hepatitis B | 52/52 | 2/45 0/46 | 5/0 | 5.11 (0.25; 103.54) | 0.04 (-0.03; 0.12) | 23
Hordeolum | 52/52 | 0/45 0/46 | | | 0.00 (-0.04; 0.04)
Allergic rhinitis | 52/52 | 2/45 0/46 | 5/0 | 5.11 (0.25; 103.54) | 0.04 (-0.03; 0.12) | 23
HBV DNA PCR-negative | 52/52 | 18/45 25/46 | 40/54 | 0.74 (0.47; 1.15) | -0.14 (-0.35; 0.06) | -7
HBeAg loss | 52/52 | 9/45 12/46 | 21/26 | 0.77 (0.36; 1.64) | -0.06 (-0.23; 0.11) | -16
HBeAg seroconversion | 52/52 | 9/45 11/46 | 19/24 | 0.84 (0.38; 1.82) | -0.04 (-0.21; 0.13) | -26
Primary treatment failure | 52/52 | 13/45 5/46 | 29/11 | 2.66 (1.03; 6.84) | 0.18 (0.02; 0.34) | 6
Adjusted for baseline covariates (baseline HBV DNA level, age, body mass index, sex, and study site) odds ratio of HBV DNA PCR-negative | 52/52 | 0/45 0/46 | | 0.84 (0.31; 2.27)
Adjusted odds ratio of HBeAg loss | 52/52 | 0/45 0/46 | | 1.19 (0.39; 3.70)
Adjusted odds ratio of HBeAg seroconversion | 52/52 | 0/45 0/46 | | 1.12 (0.35; 3.57)
Adjusted odds ratio of primary treatment failure | 52/52 | 0/45 0/46 | | 2.50 (0.60; 10.00)
Hadziyannis 2003^41^ Adefovir dipivoxil, 10 mg daily, 48 weeks | Placebo, 48 weeks | ALT normalization | 48/48 | 84/123 17/61 | 68/28 | 2.45 (1.61; 3.73) | 0.40 (0.26; 0.54) | 2
Hadziyannis 2003^41^ Adefovir dipivoxil, 10 mg daily, 48 weeks | Placebo, 48 weeks
Hadziyannis 2003^41^ Adefovir dipivoxil, 10 mg daily, 48 weeks | Placebo, 48 weeks | At least one adverse event | 48/48 | 94/123 45/61 | 76/74 | 1.04 (0.87; 1.24) | 0.03 (-0.11; 0.16) | 38
Hadziyannis 2003^41^ Adefovir dipivoxil, 10 mg daily, 48 weeks | Placebo, 48 weeks
Hadziyannis 2003^41^ Adefovir dipivoxil, 10 mg daily, 48 weeks | Placebo, 48 weeks | Severe (grade 3 or 4) adverse events | 48/48 | 7/123 6/61 | 6/10 | 0.58 (0.20; 1.65) | -0.04 (-0.13; 0.04) | -24
Hadziyannis 2003^41^ Adefovir dipivoxil, 10 mg daily, 48 weeks | Placebo, 48 weeks
Hadziyannis 2003^41^ Adefovir dipivoxil, 10 mg daily, 48 weeks | Placebo, 48 weeks | Serious adverse events not related to treatment | 48/48 | 4/123 4/61 | 3/7 | 0.50 (0.13; 1.92) | -0.03 (-0.10; 0.04) | -30
Hadziyannis 2003^41^ Adefovir dipivoxil, 10 mg daily, 48 weeks | Placebo, 48 weeks
Hadziyannis 2003^41^ Adefovir dipivoxil, 10 mg daily, 48 weeks | Placebo, 48 weeks | Any adverse event | 48/48 | 94/123 45/61 | 76/74 | 1.04 (0.87; 1.24) | 0.03 (-0.11; 0.16) | 38
Hadziyannis 2003^41^ Adefovir dipivoxil, 10 mg daily, 48 weeks | Placebo, 48 weeks
Hadziyannis 2003^41^ Adefovir dipivoxil, 10 mg daily, 48 weeks | Placebo, 48 weeks | Headache | 48/48 | 29/123 10/61 | 24/16 | 1.44 (0.75; 2.75) | 0.07 (-0.05; 0.19) | 14
Hadziyannis 2003^41^ Adefovir dipivoxil, 10 mg daily, 48 weeks | Placebo, 48 weeks
Hadziyannis 2003^41^ Adefovir dipivoxil, 10 mg daily, 48 weeks | Placebo, 48 weeks | Pharyngitis | 48/48 | 23/123 14/61 | 19/23 | 0.81 (0.45; 1.47) | -0.04 (-0.17; 0.08) | -24
Hadziyannis 2003^41^ Adefovir dipivoxil, 10 mg daily, 48 weeks | Placebo, 48 weeks
Hadziyannis 2003^41^ Adefovir dipivoxil, 10 mg daily, 48 weeks | Placebo, 48 weeks | Abdominal pain | 48/48 | 18/123 3/61 | 15/5 | 2.98 (0.91; 9.71) | 0.10 (0.01; 0.18) | 10
Hadziyannis 2003^41^ Adefovir dipivoxil, 10 mg daily, 48 weeks | Placebo, 48 weeks
Hadziyannis 2003^41^ Adefovir dipivoxil, 10 mg daily, 48 weeks | Placebo, 48 weeks | Asthenia | 48/48 | 16/123 10/61 | 13/16 | 0.79 (0.38; 1.64) | -0.03 (-0.14; 0.08) | -30
Hadziyannis 2003^41^ Adefovir dipivoxil, 10 mg daily, 48 weeks | Placebo, 48 weeks
Hadziyannis 2003^41^ Adefovir dipivoxil, 10 mg daily, 48 weeks | Placebo, 48 weeks | Influenza-like syndrome | 48/48 | 13/123 13/61 | 11/21 | 0.50 (0.25; 1.00) | -0.11 (-0.22; 0.01) | -9
Hadziyannis 2003^41^ Adefovir dipivoxil, 10 mg daily, 48 weeks | Placebo, 48 weeks
Hadziyannis 2003^41^ Adefovir dipivoxil, 10 mg daily, 48 weeks | Placebo, 48 weeks | Back pain | 48/48 | 12/123 4/61 | 10/7 | 1.49 (0.50; 4.42) | 0.03 (-0.05; 0.11) | 31
Hadziyannis 2003^41^ Adefovir dipivoxil, 10 mg daily, 48 weeks | Placebo, 48 weeks
Hadziyannis 2003^41^ Adefovir dipivoxil, 10 mg daily, 48 weeks | Placebo, 48 weeks | Pain | 48/48 | 10/123 6/61 | 8/10 | 0.83 (0.32; 2.17) | -0.02 (-0.11; 0.07) | -59
Hadziyannis 2003^41^ Adefovir dipivoxil, 10 mg daily, 48 weeks | Placebo, 48 weeks
Increased cough | 48/48 | 10/123 4/61 | 8/7 | 1.24 (0.41; 3.79) | 0.02 (-0.06; 0.09) | 64
Insomnia | 48/48 | 6/123 4/61 | 5/7 | 0.74 (0.22; 2.54) | -0.02 (-0.09; 0.06) | -60
Dyspepsia | 48/48 | 6/123 2/61 | 5/3 | 1.49 (0.31; 7.16) | 0.02 (-0.04; 0.07) | 63
Rhinitis | 48/48 | 6/123 1/61 | 5/2 | 2.98 (0.37; 24.17) | 0.03 (-0.02; 0.08) | 31
Histological improvement = reduction of at least 2 points in the Knodell necroinflammatory score, with no worsening of fibrosis | 48/48 | 77/123 19/61 | 63/31 | 2.01 (1.35; 2.99) | 0.31 (0.17; 0.46) | 3
Improved necroinflammatory activity | 48/48 | 98/123 26/61 | 80/42 | 1.87 (1.38; 2.53) | 0.37 (0.23; 0.51) | 3
Unchanged necroinflammatory activity | 48/48 | 21/123 4/61 | 17/7 | 2.60 (0.93; 7.25) | 0.11 (0.01; 0.20) | 10
Worse necroinflammatory activity | 48/48 | 4/123 31/61 | 3/51 | 0.06 (0.02; 0.17) | -0.48 (-0.60; -0.35) | -2
Improved fibrosis | 48/48 | 59/123 15/61 | 48/25 | 1.95 (1.21; 3.14) | 0.23 (0.09; 0.37) | 4
Unchanged fibrosis | 48/48 | 58/123 22/61 | 47/36 | 1.31 (0.89; 1.92) | 0.11 (-0.04; 0.26) | 9
Worse fibrosis | 48/48 | 5/123 23/61 | 4/38 | 0.11 (0.04; 0.27) | -0.34 (-0.46; -0.21) | -3
Undetectable HBV DNA | 48/48 | 63/123 0/61 | 51/0 | 63.50 (4.00; 1009.28) | 0.51 (0.42; 0.60) | 2
HBV polymerase gene mutations | 48/48 | 0/123 3/61 | 0/5 | 0.07 (0.00; 1.36) | -0.05 (-0.11; 0.01) | -20
Marcellin, 2003^126^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Adefovir dipivoxil, 30 mg/day, 48 weeks | Normalization of ALT | 48/48 | 81/171 93/173 | 47/54 | 0.88 (0.71; 1.09) | -0.06 (-0.17; 0.04) | -16
Adefovir dipivoxil, 30 mg/day, 48 weeks | Placebo, 48 weeks | Normalization of ALT | 48/48 | 81/171 26/167 | 47/16 | 3.04 (2.07; 4.48) | 0.32 (0.23; 0.41) | 3
Adefovir dipivoxil, 30 mg/day, 48 weeks
Adefovir dipivoxil, 30 mg/day, 48 weeks | Placebo, 48 weeks | Normalization of ALT | 48/48 | 93/173 26/167 | 54/16 | 3.45 (2.36; 5.05) | 0.38 (0.29; 0.47) | 3
Adefovir dipivoxil, 30 mg/day, 48 weeks | Increases in ALT to >10 times ULN | 48/48 | 17/171 14/173 | 10/8 | 1.23 (0.63; 2.41) | 0.02 (-0.04; 0.08) | 54
Placebo, 48 weeks | Increases in ALT to >10 times ULN | 48/48 | 17/171 32/167 | 10/19 | 0.52 (0.30; 0.90) | -0.09 (-0.17; -0.02) | -11
Adefovir dipivoxil, 30 mg/day, 48 weeks | Placebo, 48 weeks | Increases in ALT >10 times ULN | 48/48 | 14/173 32/167 | 8/19 | 0.42 (0.23; 0.76) | -0.11 (-0.18; -0.04) | -9
Adefovir dipivoxil, 10 mg/day, 48 weeks | Adefovir dipivoxil, 30 mg/day, 48 weeks | Discontinuation | 48/48 | 12/171 14/173 | 7/8 | 0.87 (0.41; 1.82) | -0.01 (-0.07; 0.05) | -93
Adefovir dipivoxil, 10 mg/day, 48 weeks | Placebo, 48 weeks | Discontinuation | 48/48 | 12/171 13/167 | 7/8 | 0.90 (0.42; 1.92) | -0.01 (-0.06; 0.05) | -130
Adefovir dipivoxil, 30 mg/day, 48 weeks | Placebo, 48 weeks | Discontinuation | 48/48 | 14/173 13/167 | 8/8 | 1.04 (0.50; 2.15) | 0.00 (-0.05; 0.06) | 325
Adefovir dipivoxil, 10 mg/day, 48 weeks | Adefovir dipivoxil, 30 mg/day, 48 weeks | Severe (grade 3 or 4) clinical adverse events | 48/48 | 17/171 16/173 | 10/9 | 1.07 (0.56; 2.06) | 0.01 (-0.06; 0.07) | 144
Adefovir dipivoxil, 10 mg/day, 48 weeks | Placebo, 48 weeks | Severe (grade 3 or 4) clinical adverse events | 48/48 | 17/171 13/167 | 10/8 | 1.28 (0.64; 2.55) | 0.02 (-0.04; 0.08) | 46
Adefovir dipivoxil, 30 mg/day, 48 weeks | Placebo, 48 weeks | Severe (grade 3 or 4) clinical adverse events | 48/48 | 16/173 13/167 | 9/8 | 1.19 (0.59; 2.39) | 0.01 (-0.04; 0.07) | 68
Adefovir dipivoxil, 10 mg/day, 48 weeks | Adefovir dipivoxil, 30 mg/day, 48 weeks | Discontinuation due to adverse events | 48/48 | 3/171 5/173 | 2/3 | 0.61 (0.15; 2.50) | -0.01 (-0.04; 0.02) | -88
Adefovir dipivoxil, 10 mg/day, 48 weeks | Placebo, 48 weeks | Discontinuation due to adverse events | 48/48 | 3/171 2/167 | 2/1 | 1.46 (0.25; 8.66) | 0.01 (-0.02; 0.03) | 180
Adefovir dipivoxil, 30 mg/day, 48 weeks | Placebo, 48 weeks | Discontinuation due to adverse events | 48/48 | 5/173 2/167 | 3/1 | 2.41 (0.47; 12.27) | 0.02 (-0.01; 0.05) | 59
Marcellin, 2003^126^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Adefovir dipivoxil, 30 mg/day, 48 weeks | Increases from baseline of 0.5mg per deciliter (44 μmol per liter) or greater in the serum creatinine level | 48/48 | 0/171 14/173 | 0/8 | 0.03 (0.00; 0.58) | -0.08 (-0.12; -0.04) | -12
Marcellin, 2003^126^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Adefovir dipivoxil, 30 mg/day, 48 weeks
Marcellin, 2003^126^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Adefovir dipivoxil, 30 mg/day, 48 weeks | Headache | 48/48 | 43/171 45/173 | 25/26 | 0.97 (0.67; 1.39) | -0.01 (-0.10; 0.08) | -116
Marcellin, 2003^126^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Adefovir dipivoxil, 30 mg/day, 48 weeks
Marcellin, 2003^126^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Adefovir dipivoxil, 30 mg/day, 48 weeks | Asthenia | 48/48 | 42/171 45/173 | 25/26 | 0.94 (0.66; 1.36) | -0.01 (-0.11; 0.08) | -69
Marcellin, 2003^126^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Adefovir dipivoxil, 30 mg/day, 48 weeks
Marcellin, 2003^126^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Adefovir dipivoxil, 30 mg/day, 48 weeks | Abdominal pain | 48/48 | 31/171 38/173 | 18/22 | 0.83 (0.54; 1.26) | -0.04 (-0.12; 0.05) | -26
Marcellin, 2003^126^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Adefovir dipivoxil, 30 mg/day, 48 weeks
Marcellin, 2003^126^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Adefovir dipivoxil, 30 mg/day, 48 weeks | Flu-like syndrome | 48/48 | 28/171 32/173 | 16/18 | 0.89 (0.56; 1.40) | -0.02 (-0.10; 0.06) | -47
Marcellin, 2003^126^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Adefovir dipivoxil, 30 mg/day, 48 weeks
Marcellin, 2003^126^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Adefovir dipivoxil, 30 mg/day, 48 weeks | Pain | 48/48 | 19/171 13/173 | 11/8 | 1.48 (0.75; 2.90) | 0.04 (-0.03; 0.10) | 28
Marcellin, 2003^126^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Adefovir dipivoxil, 30 mg/day, 48 weeks
Marcellin, 2003^126^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Adefovir dipivoxil, 30 mg/day, 48 weeks | Back pain | 48/48 | 11/171 17/173 | 6/10 | 0.65 (0.32; 1.36) | -0.03 (-0.09; 0.02) | -29
Marcellin, 2003^126^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Adefovir dipivoxil, 30 mg/day, 48 weeks
Marcellin, 2003^126^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Nausea | 48/48 | 17/171 31/173 | 10/18 | 0.55 (0.32; 0.96) | -0.08 (-0.15; -0.01) | -13
Marcellin, 2003^126^ Adefovir dipivoxil, 10 mg/day, 48 weeks
Marcellin, 2003^126^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Diarrhea | 48/48 | 23/171 25/173 | 13/14 | 0.93 (0.55; 1.57) | -0.01 (-0.08; 0.06) | -100
Marcellin, 2003^126^ Adefovir dipivoxil, 10 mg/day, 48 weeks
Marcellin, 2003^126^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Dyspepsia | 48/48 | 15/171 19/173 | 9/11 | 0.80 (0.42; 1.52) | -0.02 (-0.09; 0.04) | -45
Marcellin, 2003^126^ Adefovir dipivoxil, 10 mg/day, 48 weeks
Marcellin, 2003^126^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Flatulence | 48/48 | 13/171 18/173 | 8/10 | 0.73 (0.37; 1.44) | -0.03 (-0.09; 0.03) | -36
Marcellin, 2003^126^ Adefovir dipivoxil, 10 mg/day, 48 weeks
Marcellin, 2003^126^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Anorexia | 48/48 | 6/171 18/173 | 4/10 | 0.34 (0.14; 0.83) | -0.07 (-0.12; -0.02) | -15
Marcellin, 2003^126^ Adefovir dipivoxil, 10 mg/day, 48 weeks
Marcellin, 2003^126^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Dizziness | 48/48 | 9/171 18/173 | 5/10 | 0.51 (0.23; 1.09) | -0.05 (-0.11; 0.01) | -19
Marcellin, 2003^126^ Adefovir dipivoxil, 10 mg/day, 48 weeks
Marcellin, 2003^126^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Pharyngitis | 48/48 | 44/171 70/173 | 26/40 | 0.64 (0.47; 0.87) | -0.15 (-0.25; -0.05) | -7
Marcellin, 2003^126^ Adefovir dipivoxil, 10 mg/day, 48 weeks
Increased cough | 48/48 | 11/171 19/173 | 6/11 | 0.59 (0.29; 1.19) | -0.05 (-0.10; 0.01) | -22
Placebo, 48 weeks | Headache | 48/48 | 43/171 37/167 | 25/22 | 1.13 (0.77; 1.67) | 0.03 (-0.06; 0.12) | 33
Placebo, 48 weeks
Placebo, 48 weeks | Asthenia | 48/48 | 42/171 32/167 | 25/19 | 1.28 (0.85; 1.93) | 0.05 (-0.03; 0.14) | 19
Placebo, 48 weeks
Placebo, 48 weeks | Abdominal pain | 48/48 | 31/171 32/167 | 18/19 | 0.95 (0.61; 1.48) | -0.01 (-0.09; 0.07) | -97
Placebo, 48 weeks
Placebo, 48 weeks | Flu-like syndrome | 48/48 | 28/171 31/167 | 16/19 | 0.88 (0.55; 1.40) | -0.02 (-0.10; 0.06) | -46
Placebo, 48 weeks
Placebo, 48 weeks | Pain | 48/48 | 19/171 21/167 | 11/13 | 0.88 (0.49; 1.58) | -0.01 (-0.08; 0.05) | -68
Placebo, 48 weeks
Placebo, 48 weeks | Back pain | 48/48 | 11/171 11/167 | 6/7 | 0.98 (0.44; 2.19) | 0.00 (-0.05; 0.05) | -649
Placebo, 48 weeks
Placebo, 48 weeks | Nausea | 48/48 | 17/171 23/167 | 10/14 | 0.72 (0.40; 1.30) | -0.04 (-0.11; 0.03) | -26
Diarrhea | 48/48 | 23/171 13/167 | 13/8 | 1.73 (0.91; 3.30) | 0.06 (-0.01; 0.12) | 18
Dyspepsia | 48/48 | 15/171 14/167 | 9/8 | 1.05 (0.52; 2.10) | 0.00 (-0.06; 0.06) | 257
Flatulence | 48/48 | 13/171 10/167 | 8/6 | 1.27 (0.57; 2.82) | 0.02 (-0.04; 0.07) | 62
Anorexia | 48/48 | 6/171 9/167 | 4/5 | 0.65 (0.24; 1.79) | -0.02 (-0.06; 0.03) | -53
Dizziness | 48/48 | 9/171 13/167 | 5/8 | 0.68 (0.30; 1.54) | -0.03 (-0.08; 0.03) | -40
Pharyngitis | 48/48 | 44/171 54/167 | 26/32 | 0.80 (0.57; 1.11) | -0.07 (-0.16; 0.03) | -15
Increased cough | 48/48 | 11/171 21/167 | 6/13 | 0.51 (0.25; 1.03) | -0.06 (-0.12; 0.00) | -16
Marcellin, 2003^126^ Adefovir dipivoxil, 30 mg/day, 48 weeks | Placebo, 48 weeks | Headache | 48/48 | 45/173 37/167 | 26/22 | 1.17 (0.80; 1.72) | 0.04 (-0.05; 0.13) | 26
Marcellin, 2003^126^ Adefovir dipivoxil, 30 mg/day, 48 weeks | Placebo, 48 weeks | Asthenia | 48/48 | 45/173 32/167 | 26/19 | 1.36 (0.91; 2.03) | 0.07 (-0.02; 0.16) | 15
Marcellin, 2003^126^ Adefovir dipivoxil, 30 mg/day, 48 weeks | Placebo, 48 weeks | Abdominal pain | 48/48 | 38/173 32/167 | 22/19 | 1.15 (0.75; 1.74) | 0.03 (-0.06; 0.11) | 36
Marcellin, 2003^126^ Adefovir dipivoxil, 30 mg/day, 48 weeks | Placebo, 48 weeks | Flu-like syndrome | 48/48 | 32/173 31/167 | 18/19 | 1.00 (0.64; 1.56) | 0.00 (-0.08; 0.08) | -1521
Marcellin, 2003^126^ Adefovir dipivoxil, 30 mg/day, 48 weeks | Placebo, 48 weeks | Pain | 48/48 | 13/173 21/167 | 8/13 | 0.60 (0.31; 1.15) | -0.05 (-0.11; 0.01) | -20
Marcellin, 2003^126^ Adefovir dipivoxil, 30 mg/day, 48 weeks | Placebo, 48 weeks | Back pain | 48/48 | 17/173 11/167 | 10/7 | 1.49 (0.72; 3.09) | 0.03 (-0.03; 0.09) | 31
Marcellin, 2003^126^ Adefovir dipivoxil, 30 mg/day, 48 weeks | Placebo, 48 weeks | Nausea | 48/48 | 31/173 23/167 | 18/14 | 1.30 (0.79; 2.14) | 0.04 (-0.04; 0.12) | 24
Marcellin, 2003^126^ Adefovir dipivoxil, 30 mg/day, 48 weeks | Placebo, 48 weeks | Diarrhea | 48/48 | 25/173 13/167 | 14/8 | 1.86 (0.98; 3.51) | 0.07 (0.00; 0.13) | 15
Marcellin, 2003^126^ Adefovir dipivoxil, 30 mg/day, 48 weeks | Placebo, 48 weeks | Dyspepsia | 48/48 | 19/173 14/167 | 11/8 | 1.31 (0.68; 2.53) | 0.03 (-0.04; 0.09) | 38
Marcellin, 2003^126^ Adefovir dipivoxil, 30 mg/day, 48 weeks | Placebo, 48 weeks | Flatulence | 48/48 | 18/173 10/167 | 10/6 | 1.74 (0.83; 3.65) | 0.04 (-0.01; 0.10) | 23
Marcellin, 2003^126^ Adefovir dipivoxil, 30 mg/day, 48 weeks | Placebo, 48 weeks | Anorexia | 48/48 | 18/173 9/167 | 10/5 | 1.93 (0.89; 4.18) | 0.05 (-0.01; 0.11) | 20
Marcellin, 2003^126^ Adefovir dipivoxil, 30 mg/day, 48 weeks | Placebo, 48 weeks | Dizziness | 48/48 | 18/173 13/167 | 10/8 | 1.34 (0.68; 2.64) | 0.03 (-0.03; 0.09) | 38
Marcellin, 2003^126^ Adefovir dipivoxil, 30 mg/day, 48 weeks | Placebo, 48 weeks | Pharyngitis | 48/48 | 70/173 54/167 | 40/32 | 1.25 (0.94; 1.66) | 0.08 (-0.02; 0.18) | 12
Increased cough | 48/48 | 19/173 21/167 | 11/13 | 0.87 (0.49; 1.56) | -0.02 (-0.08; 0.05) | -63
Adefovir dipivoxil, 10 mg/day, 48 weeks | Adefovir dipivoxil, 30 mg/day, 48 weeks | Histological improvement was defined as a decrease of at least 2 points in the Knodell necroinflammatory score from baseline to week 48, with no concurrent worsening of the Knodell fibrosis score | 48/48 | 89/171 98/173 | 52/57 | 0.92 (0.76; 1.12) | -0.05 (-0.15; 0.06) | -22
Adefovir dipivoxil, 10 mg/day, 48 weeks | Placebo, 48 weeks | Histological improvement was defined as a decrease of at least 2 points in the Knodell necroinflammatory score from baseline to week 48, with no concurrent worsening of the Knodell fibrosis score | 48/48 | 89/171 41/167 | 52/25 | 2.12 (1.57; 2.87) | 0.27 (0.18; 0.37) | 4
Adefovir dipivoxil, 30 mg/day, 48 weeks | Placebo, 48 weeks | 48/48 | 96/173 41/167 | 55/25 | 2.26 (1.68; 3.04) | 0.31 (0.21; 0.41) | 3
Adefovir dipivoxil, 10 mg/day, 48 weeks | Adefovir dipivoxil, 30 mg/day, 48 weeks | No histological improvement | 48/48 | 61/171 47/173 | 36/27 | 1.31 (0.96; 1.80) | 0.09 (-0.01; 0.18) | 12
Adefovir dipivoxil, 10 mg/day, 48 weeks | Placebo, 48 weeks | No histological improvement | 48/48 | 61/171 105/167 | 36/63 | 0.57 (0.45; 0.72) | -0.27 (-0.37; -0.17) | -4
Adefovir dipivoxil, 30 mg/day, 48 weeks | Placebo, 48 weeks | No histological improvement | 48/48 | 47/173 105/167 | 27/63 | 0.43 (0.33; 0.57) | -0.36 (-0.46; -0.26) | -3
Adefovir dipivoxil, 10 mg/day, 48 weeks | Placebo, 48 weeks | Relative risk of histological improvement defined as a decrease of at least 2 points in the Knodell necroinflammatory score from baseline to week 48, with no concurrent worsening of the Knodell fibrosis score adjusted for 7 locations (countries) | 48/48 | 0/171 0/167 | | 2.10 (1.60; 2.80)
Adefovir dipivoxil, 30 mg/day, 48 weeks | Placebo, 48 weeks | 48/48 | 0/173 0/167 | | 2.30 (1.70; 3.10)
Adefovir dipivoxil, 10 mg/day, 48 weeks | Adefovir dipivoxil, 30 mg/day, 48 weeks | Change in Knodell necroinflammatory activity scores | 48/48 | 107/171 112/173 | 63/65 | 0.97 (0.82; 1.13) | -0.02 (-0.12; 0.08) | -46
Adefovir dipivoxil, 10 mg/day, 48 weeks | Adefovir dipivoxil, 30 mg/day, 48 weeks | No change in Knodell necroinflammatory activity scores | 48/48 | 23/171 18/173 | 13/10 | 1.29 (0.72; 2.31) | 0.03 (-0.04; 0.10) | 33
Adefovir dipivoxil, 10 mg/day, 48 weeks | Worse Knodell necroinflammatory activity scores | 48/48 | 20/171 15/173 | 12/9 | 1.35 (0.71; 2.55) | 0.03 (-0.03; 0.09) | 33
Adefovir dipivoxil, 10 mg/day, 48 weeks | Placebo, 48 weeks | Change in Knodell necroinflammatory activity scores | 48/48 | 107/171 59/167 | 63/35 | 1.77 (1.40; 2.24) | 0.27 (0.17; 0.37) | 4
Adefovir dipivoxil, 10 mg/day, 48 weeks | Placebo, 48 weeks | No change in Knodell necroinflammatory activity scores | 48/48 | 23/171 37/167 | 13/22 | 0.61 (0.38; 0.98) | -0.09 (-0.17; -0.01) | -11
Worse Knodell necroinflammatory activity scores | 48/48 | 20/171 49/167 | 12/29 | 0.40 (0.25; 0.64) | -0.18 (-0.26; -0.09) | -6
Marcellin, 2003^42^ Adefovir dipivoxil, 30 mg/day, 48 weeks | Placebo, 48 weeks | Change in Knodell necroinflammatory activity scores | 48/48 | 112/173 59/167 | 65/35 | 1.83 (1.45; 2.31) | 0.29 (0.19; 0.40) | 3
Marcellin, 2003^42^ Adefovir dipivoxil, 30 mg/day, 48 weeks | Placebo, 48 weeks | No change in Knodell necroinflammatory activity scores | 48/48 | 18/173 37/167 | 10/22 | 0.47 (0.28; 0.79) | -0.12 (-0.20; -0.04) | -9
Worse Knodell necroinflammatory activity scores | 48/48 | 15/173 49/167 | 9/29 | 0.30 (0.17; 0.51) | -0.21 (-0.29; -0.13) | -5
Marcellin, 2003^42^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Adefovir dipivoxil, 30 mg/day, 48 weeks | Change in Knodell fibrosis scores | 48/48 | 62/171 78/173 | 36/45 | 0.80 (0.62; 1.04) | -0.09 (-0.19; 0.02) | -11
Marcellin, 2003^42^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Adefovir dipivoxil, 30 mg/day, 48 weeks | No change in Knodell fibrosis scores | 48/48 | 67/171 53/173 | 39/31 | 1.28 (0.96; 1.71) | 0.09 (-0.01; 0.19) | 12
Marcellin, 2003^42^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Worse Knodell fibrosis scores | 48/48 | 21/171 14/173 | 12/8 | 1.52 (0.80; 2.88) | 0.04 (-0.02; 0.11) | 24
Marcellin, 2003^42^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Placebo, 48 weeks | Change in Knodell fibrosis scores | 48/48 | 62/171 35/167 | 36/21 | 1.73 (1.21; 2.47) | 0.15 (0.06; 0.25) | 7
Marcellin, 2003^42^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Placebo, 48 weeks | No change in Knodell fibrosis scores | 48/48 | 67/171 72/167 | 39/43 | 0.91 (0.70; 1.17) | -0.04 (-0.14; 0.07) | -25
Worse Knodell fibrosis scores | 48/48 | 21/171 38/167 | 12/23 | 0.54 (0.33; 0.88) | -0.10 (-0.19; -0.02) | -10
Marcellin, 2003^42^ Adefovir dipivoxil, 30 mg/day, 48 weeks | Placebo, 48 weeks | Change in Knodell fibrosis scores | 48/48 | 78/173 35/167 | 45/21 | 2.15 (1.54; 3.01) | 0.24 (0.14; 0.34) | 4
Marcellin, 2003^42^ Adefovir dipivoxil, 30 mg/day, 48 weeks | Placebo, 48 weeks | No change in Knodell fibrosis scores | 48/48 | 53/173 72/167 | 31/43 | 0.71 (0.53; 0.94) | -0.12 (-0.23; -0.02) | -8
Worse Knodell Fibrosis scores | 48/48 | 14/173 38/167 | 8/23 | 0.36 (0.20; 0.63) | -0.15 (-0.22; -0.07) | -7
Marcellin, 2003^42^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Adefovir dipivoxil, 30 mg/day, 48 weeks | HBV DNA <400 copies/ml | 48/48 | 36/171 67/173 | 21/39 | 0.54 (0.38; 0.77) | -0.18 (-0.27; -0.08) | -6
Placebo, 48 weeks | HBV DNA <400 copies/ml | 48/48 | 36/171 0/167 | 21/0 | 71.30 (4.41; 1152.34) | 0.21 (0.15; 0.27) | 5
Marcellin, 2003^42^ Adefovir dipivoxil, 30 mg/day, 48 weeks | Placebo, 48 weeks | HBV DNA <400 copies/ml | 48/48 | 67/173 0/167 | 39/0 | 130.34 (8.14; 2088.39) | 0.39 (0.31; 0.46) | 3
Marcellin, 2003^42^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Adefovir dipivoxil, 30 mg/day, 48 weeks | HBeAg seroconversion | 48/48 | 20/171 23/173 | 12/13 | 0.88 (0.50; 1.54) | -0.02 (-0.09; 0.05) | -63
Placebo, 48 weeks | HBeAg seroconversion | 48/48 | 20/171 9/167 | 12/5 | 2.17 (1.02; 4.63) | 0.06 (0.00; 0.12) | 16
Marcellin, 2003^42^ Adefovir dipivoxil, 30 mg/day, 48 weeks | Placebo, 48 weeks | HBeAg seroconversion | 48/48 | 23/173 9/167 | 13/5 | 2.47 (1.18; 5.17) | 0.08 (0.02; 0.14) | 13
Marcellin, 2003^42^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Adefovir dipivoxil, 30 mg/day, 48 weeks | HBeAg loss | 48/48 | 41/171 44/173 | 24/25 | 0.94 (0.65; 1.36) | -0.01 (-0.11; 0.08) | -69
Placebo, 48 weeks | HBeAg loss | 48/48 | 41/171 17/167 | 24/10 | 2.36 (1.40; 3.98) | 0.14 (0.06; 0.22) | 7
Marcellin, 2003^42^ Adefovir dipivoxil, 30 mg/day, 48 weeks | Placebo, 48 weeks | HBeAg loss | 48/48 | 44/173 17/167 | 25/10 | 2.50 (1.49; 4.19) | 0.15 (0.07; 0.23) | 7
Westland, 2003^100^ Adefovir dipivoxil, 20 mg/day (10 or 30 mg), 48 weeks | Placebo, 48 weeks | Emerging amino acid substitutions in the HBV-RT domain | 48/48 | 130/467 137/228 | 28/60 | 0.46 (0.39; 0.55) | -0.32 (-0.40; -0.25) | -3
Westland, 2003^100^ Adefovir dipivoxil, 20 mg/day (10 or 30 mg), 48 weeks | Placebo, 48 weeks | Amino acid substitutions rt221Y | 48/48 | 1/467 7/228 | 0/3 | 0.07 (0.01; 0.56) | -0.03 (-0.05; -0.01) | -35
Westland, 2003^100^ Adefovir dipivoxil, 20 mg/day (10 or 30 mg), 48 weeks | Placebo, 48 weeks | Amino acid substitutions rt134D | 48/48 | 4/467 2/228 | 1/1 | 0.98 (0.18; 5.29) | 0.00 (-0.01; 0.01) | -4840
Westland, 2003^100^ Adefovir dipivoxil, 20 mg/day (10 or 30 mg), 48 weeks | Placebo, 48 weeks | Amino acid substitutions rt219A | 48/48 | 3/467 3/228 | 1/1 | 0.49 (0.10; 2.40) | -0.01 (-0.02; 0.01) | -149
Westland, 2003^100^ Adefovir dipivoxil, 20 mg/day (10 or 30 mg), 48 weeks | Placebo, 48 weeks | Amino acid substitutions rt91I | 48/48 | 1/467 4/228 | 0/2 | 0.12 (0.01; 1.09) | -0.02 (-0.03; 0.00) | -65
Westland, 2003^100^ Adefovir dipivoxil, 20 mg/day (10 or 30 mg), 48 weeks | Placebo, 48 weeks | Amino acid substitutions rt134N | 48/48 | 1/467 4/228 | 0/2 | 0.12 (0.01; 1.09) | -0.02 (-0.03; 0.00) | -65
Westland, 2003^100^ Adefovir dipivoxil, 20 mg/day (10 or 30 mg), 48 weeks | Placebo, 48 weeks | Amino acid substitutions rt54H | 48/48 | 3/467 1/228 | 1/0 | 1.46 (0.15; 14.00) | 0.00 (-0.01; 0.01) | 491
Westland, 2003^100^ Adefovir dipivoxil, 20 mg/day (10 or 30 mg), 48 weeks | Placebo, 48 weeks | Amino acid substitutions rt145M | 48/48 | 0/467 4/228 | 0/2 | 0.05 (0.00; 1.01) | -0.02 (-0.04; 0.00) | -57
Westland, 2003^100^ Adefovir dipivoxil, 20 mg/day (10 or 30 mg), 48 weeks | Placebo, 48 weeks | Substitutions emerged at conserved sites in the HBV polymerase/RT | 48/48 | 4/467 6/228 | 1/3 | 0.33 (0.09; 1.14) | -0.02 (-0.04; 0.00) | -56
Unconfirmed (i.e., occurring at one visit only) 1.0 log10 or greater increase in serum HBV-DNA level | 48/48 | 24/467 63/228 | 5/28 | 0.19 (0.12; 0.29) | -0.22 (-0.29; -0.16) | -4
Perrillo, 2004^58^ Adefovir dipivoxil, 10 mg/day for 52 weeks Lamivudine, 100mg/day for at least 6 months, 52 weeks | Lamivudine, 100 mg/day, 52 weeks | Normalization ALT | 52/52 | 14/46 3/49 | 30/6 | 4.97 (1.53; 16.18) | 0.24 (0.09; 0.39) | 4
Perrillo, 2004^58^ Adefovir dipivoxil, 10 mg/day for 52 weeks Lamivudine, 100mg/day for at least 6 months, 52 weeks | Lamivudine, 100 mg/day, 52 weeks | At least 1 adverse event | 52/52 | 36/46 40/49 | 78/82 | 0.96 (0.78; 1.17) | -0.03 (-0.19; 0.13) | -30
Perrillo, 2004^58^ Adefovir dipivoxil, 10 mg/day for 52 weeks Lamivudine, 100mg/day for at least 6 months, 52 weeks | Lamivudine, 100 mg/day, 52 weeks | HBV DNA level <10 in 5 degree copies/ mL or a 2 log10 copies/mL reduction from baseline HBV DNA | 52/52 | 39/46 5/49 | 85/10 | 8.31 (3.59; 19.24) | 0.75 (0.61; 0.88) | 1
Perrillo, 2004^58^ Adefovir dipivoxil, 10 mg/day for 52 weeks Lamivudine, 100mg/day for at least 6 months, 52 weeks | Lamivudine, 100 mg/day, 52 weeks | HBV DNA negative by polymerase chain reaction (200 copies/ml) | 52/52 | 9/46 0/49 | 20/0 | 20.21 (1.21; 337.68) | 0.20 (0.08; 0.31) | 5
Perrillo, 2004^58^ Adefovir dipivoxil, 10 mg/day for 52 weeks Lamivudine, 100mg/day for at least 6 months, 52 weeks | Lamivudine, 100 mg/day, 52 weeks | HBeAg loss | 52/52 | 6/46 1/49 | 13/2 | 6.39 (0.80; 51.08) | 0.11 (0.00; 0.22) | 9
Perrillo, 2004^58^ Adefovir dipivoxil, 10 mg/day for 52 weeks Lamivudine, 100mg/day for at least 6 months, 52 weeks | Lamivudine, 100 mg/day, 52 weeks | Detectable YMDD mutant | 52/52 | 26/46 44/49 | 57/90 | 0.63 (0.48; 0.82) | -0.33 (-0.50; -0.17) | -3
Perrillo, 2004^58^ Adefovir dipivoxil, 10 mg/day for 52 weeks Lamivudine, 100mg/day for at least 6 months, 52 weeks | Lamivudine, 100 mg/day, 52 weeks | HBV DNA negative (<500 copies/ml) | 52/52 | 14/46 2/49 | 30/4 | 7.46 (1.79; 31.03) | 0.26 (0.12; 0.41) | 4
Perrillo, 2004^58^ Adefovir dipivoxil, 10 mg/day for 52 weeks Lamivudine, 100mg/day for at least 6 months, 52 weeks | Lamivudine, 100 mg/day, 52 weeks | Wild type mutation | 52/52 | 2/46 0/49 | 4/0 | 5.32 (0.26; 107.93) | 0.04 (-0.03; 0.11) | 23
HBeAg seroconversion | 52/52 | 3/46 1/49 | 7/2 | 3.20 (0.34; 29.63) | 0.04 (-0.04; 0.13) | 22
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Lamivudine, 100 mg/day, 48 weeks | Normalization ALT | 48/48 | 10/20 1/19 | 50/5 | 9.50 (1.34; 67.27) | 0.45 (0.21; 0.69) | 2
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | Normalization ALT | 48/48 | 10/20 9/19 | 50/47 | 1.06 (0.55; 2.01) | 0.03 (-0.29; 0.34) | 38
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Lamivudine, 100 mg/day, 48 weeks | Any adverse event | 48/48 | 18/20 19/19 | 90/100 | 0.90 (0.76; 1.07) | -0.10 (-0.25; 0.05) | -10
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Lamivudine, 100 mg/day, 48 weeks | Asthenia | 48/48 | 10/20 6/19 | 50/32 | 1.58 (0.72; 3.50) | 0.18 (-0.12; 0.49) | 5
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Lamivudine, 100 mg/day, 48 weeks | Headache | 48/48 | 6/20 5/19 | 30/26 | 1.14 (0.42; 3.12) | 0.04 (-0.25; 0.32) | 27
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Lamivudine, 100 mg/day, 48 weeks | Pharyngitis | 48/48 | 1/20 6/19 | 5/32 | 0.16 (0.02; 1.20) | -0.27 (-0.50; -0.04) | -4
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Lamivudine, 100 mg/day, 48 weeks | Abdominal pain | 48/48 | 6/20 5/19 | 30/26 | 1.14 (0.42; 3.12) | 0.04 (-0.25; 0.32) | 27
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Lamivudine, 100 mg/day, 48 weeks | Insomnia | 48/48 | 0/20 2/19 | 0/11 | 0.19 (0.01; 3.73) | -0.11 (-0.26; 0.05) | -9
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Lamivudine, 100 mg/day, 48 weeks | Rash | 48/48 | 0/20 4/19 | 0/21 | 0.11 (0.01; 1.84) | -0.21 (-0.40; -0.02) | -5
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Lamivudine, 100 mg/day, 48 weeks | Fever | 48/48 | 0/20 1/19 | 0/5 | 0.32 (0.01; 7.35) | -0.05 (-0.19; 0.08) | -19
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Lamivudine, 100 mg/day, 48 weeks | Sinusitis | 48/48 | 1/20 5/19 | 5/26 | 0.19 (0.02; 1.48) | -0.21 (-0.43; 0.01) | -5
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Lamivudine, 100 mg/day, 48 weeks | Arthralgia | 48/48 | 1/20 3/19 | 5/16 | 0.32 (0.04; 2.79) | -0.11 (-0.30; 0.08) | -9
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Lamivudine, 100 mg/day, 48 weeks | Back pain | 48/48 | 3/20 3/19 | 15/16 | 0.95 (0.22; 4.14) | -0.01 (-0.23; 0.22) | -127
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Lamivudine, 100 mg/day, 48 weeks | Increased cough | 48/48 | 0/20 3/19 | 0/16 | 0.14 (0.01; 2.47) | -0.16 (-0.34; 0.02) | -6
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Lamivudine, 100 mg/day, 48 weeks | Nausea | 48/48 | 4/20 1/19 | 20/5 | 3.80 (0.47; 31.01) | 0.15 (-0.05; 0.35) | 7
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Lamivudine, 100 mg/day, 48 weeks | Pain | 48/48 | 4/20 4/19 | 20/21 | 0.95 (0.28; 3.27) | -0.01 (-0.26; 0.24) | -95
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Lamivudine, 100 mg/day, 48 weeks | Diarrhea | 48/48 | 2/20 6/19 | 10/32 | 0.32 (0.07; 1.38) | -0.22 (-0.46; 0.03) | -5
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Lamivudine, 100 mg/day, 48 weeks | Gastroenteritis | 48/48 | 0/20 3/19 | 0/16 | 0.14 (0.01; 2.47) | -0.16 (-0.34; 0.02) | -6
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Lamivudine, 100 mg/day, 48 weeks | Infection | 48/48 | 3/20 1/19 | 15/5 | 2.85 (0.32; 25.07) | 0.10 (-0.09; 0.28) | 10
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Lamivudine, 100 mg/day, 48 weeks | Rhinitis | 48/48 | 2/20 5/19 | 10/26 | 0.38 (0.08; 1.73) | -0.16 (-0.40; 0.07) | -6
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Bacterial infection | 48/48 | 3/20 0/19 | 15/0 | 6.67 (0.37; 121.07) | 0.15 (-0.02; 0.32) | 7
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | Any adverse event | 48/48 | 18/20 18/19 | 90/95 | 0.95 (0.79; 1.14) | -0.05 (-0.21; 0.12) | -21
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | Asthenia | 48/48 | 10/20 9/19 | 50/47 | 1.06 (0.55; 2.01) | 0.03 (-0.29; 0.34) | 38
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | Headache | 48/48 | 6/20 5/19 | 30/26 | 1.14 (0.42; 3.12) | 0.04 (-0.25; 0.32) | 27
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | Pharyngitis | 48/48 | 1/20 5/19 | 5/26 | 0.19 (0.02; 1.48) | -0.21 (-0.43; 0.01) | -5
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | Abdominal pain | 48/48 | 6/20 4/19 | 30/21 | 1.43 (0.48; 4.27) | 0.09 (-0.18; 0.36) | 11
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | Insomnia | 48/48 | 0/20 4/19 | 0/21 | 0.11 (0.01; 1.84) | -0.21 (-0.40; -0.02) | -5
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | Rash | 48/48 | 0/20 4/19 | 0/21 | 0.11 (0.01; 1.84) | -0.21 (-0.40; -0.02) | -5
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | Fever | 48/48 | 0/20 3/19 | 0/16 | 0.14 (0.01; 2.47) | -0.16 (-0.34; 0.02) | -6
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | Sinusitis | 48/48 | 1/20 3/19 | 5/16 | 0.32 (0.04; 2.79) | -0.11 (-0.30; 0.08) | -9
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | Arthralgia | 48/48 | 1/20 2/19 | 5/11 | 0.48 (0.05; 4.82) | -0.06 (-0.22; 0.11) | -18
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | Back pain | 48/48 | 3/20 2/19 | 15/11 | 1.43 (0.27; 7.61) | 0.04 (-0.16; 0.25) | 22
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | Increased cough | 48/48 | 0/20 2/19 | 0/11 | 0.19 (0.01; 3.73) | -0.11 (-0.26; 0.05) | -9
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | Nausea | 48/48 | 4/20 2/19 | 20/11 | 1.90 (0.39; 9.20) | 0.09 (-0.13; 0.32) | 11
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | Pain | 48/48 | 4/20 2/19 | 20/11 | 1.90 (0.39; 9.20) | 0.09 (-0.13; 0.32) | 11
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | Diarrhea | 48/48 | 2/20 1/19 | 10/5 | 1.90 (0.19; 19.27) | 0.05 (-0.12; 0.21) | 21
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | Gastroenteritis | 48/48 | 0/20 1/19 | 0/5 | 0.32 (0.01; 7.35) | -0.05 (-0.19; 0.08) | -19
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | Infection | 48/48 | 3/20 1/19 | 15/5 | 2.85 (0.32; 25.07) | 0.10 (-0.09; 0.28) | 10
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | Rhinitis | 48/48 | 2/20 1/19 | 10/5 | 1.90 (0.19; 19.27) | 0.05 (-0.12; 0.21) | 21
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Bacterial infection | 48/48 | 3/20 0/19 | 15/0 | 6.67 (0.37; 121.07) | 0.15 (-0.02; 0.32) | 7
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Lamivudine, 100 mg/day, 48 weeks | ALT Grade 3 (>5–10 times the ULN) | 48/48 | 1/20 0/19 | 5/0 | 2.86 (0.12; 66.11) | 0.05 (-0.08; 0.18) | 20
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Lamivudine, 100 mg/day, 48 weeks | ALT Grade 4 >10 times the ULN) | 48/48 | 1/20 3/19 | 5/16 | 0.32 (0.04; 2.79) | -0.11 (-0.30; 0.08) | -9
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Lamivudine, 100 mg/day, 48 weeks | AST Grade3 (>5–10 times the ULN) | 48/48 | 0/20 1/19 | 0/5 | 0.32 (0.01; 7.35) | -0.05 (-0.19; 0.08) | -19
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Lamivudine, 100 mg/day, 48 weeks | Grade4 (>10 times the ULN) | 48/48 | 0/20 2/19 | 0/11 | 0.19 (0.01; 3.73) | -0.11 (-0.26; 0.05) | -9
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Lamivudine, 100 mg/day, 48 weeks | Amylase Grade3 (>2–5 times the ULN) | 48/48 | 2/20 3/19 | 10/16 | 0.63 (0.12; 3.38) | -0.06 (-0.27; 0.15) | -17
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Lamivudine, 100 mg/day, 48 weeks | Grade4 (5 times the ULN) | 48/48 | 0/20 0/19 | | | 0.00 (-0.09; 0.09)
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Lamivudine, 100 mg/day, 48 weeks | Serum glucose Grade3 (30–39 mg/dL; 251–500 mg/dL) | 48/48 | 1/20 3/19 | 5/16 | 0.32 (0.04; 2.79) | -0.11 (-0.30; 0.08) | -9
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Lamivudine, 100 mg/day, 48 weeks | Grade4 (>30 mg/dL; <500 mg/dL) | 48/48 | 0/20 0/19 | | | 0.00 (-0.09; 0.09)
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Lamivudine, 100 mg/day, 48 weeks | Urine Glucose Grade3 (3+) | 48/48 | 1/20 4/19 | 5/21 | 0.24 (0.03; 1.94) | -0.16 (-0.37; 0.05) | -6
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Grade4 (4+) | 48/48 | 0/20 0/19 | | | 0.00 (-0.09; 0.09)
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | ALT Grade 3 (>5–10 times the ULN) | 48/48 | 1/20 7/19 | 5/37 | 0.14 (0.02; 1.00) | -0.32 (-0.56; -0.08) | -3
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | ALT Grade 4 >10 times the ULN) | 48/48 | 1/20 0/19 | 5/0 | 2.86 (0.12; 66.11) | 0.05 (-0.08; 0.18) | 20
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | AST Grade 3 (>5–10 times the ULN) | 48/48 | 0/20 1/19 | 0/5 | 0.32 (0.01; 7.35) | -0.05 (-0.19; 0.08) | -19
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | Grade 4 (>10 times the ULN) | 48/48 | 0/20 0/19 | | | 0.00 (-0.09; 0.09)
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | Amylase Grade 3 (>2–5 times the ULN) | 48/48 | 2/20 0/19 | 10/0 | 4.76 (0.24; 93.19) | 0.10 (-0.05; 0.25) | 10
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | Grade 4 (5 times the ULN) | 48/48 | 0/20 0/19 | | | 0.00 (-0.09; 0.09)
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | Serum Glucose Grade 3 (30–39mg/dL; 251–500 mg/dL) | 48/48 | 1/20 2/19 | 5/11 | 0.48 (0.05; 4.82) | -0.06 (-0.22; 0.11) | -18
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | Grade 4 (>30mg/dL; <500 mg/dL) | 48/48 | 0/20 0/19 | | | 0.00 (-0.09; 0.09)
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | Urine Glucose Grade3 (3+) | 48/48 | 1/20 2/19 | 5/11 | 0.48 (0.05; 4.82) | -0.06 (-0.22; 0.11) | -18
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Grade4 (4+) | 48/48 | 0/20 0/19 | | | 0.00 (-0.09; 0.09)
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Lamivudine, 100 mg/day, 48 weeks | HBV DNA undetectable | 48/48 | 7/20 0/19 | 35/0 | 14.29 (0.87; 234.09) | 0.35 (0.13; 0.57) | 3
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | HBV DNA undetectable | 48/48 | 7/20 5/19 | 35/26 | 1.33 (0.51; 3.48) | 0.09 (-0.20; 0.37) | 12
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Lamivudine, 100 mg/day, 48 weeks | HBeAg loss | 48/48 | 3/20 0/19 | 15/0 | 6.67 (0.37; 121.07) | 0.15 (-0.02; 0.32) | 7
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | HBeAg loss | 48/48 | 3/20 3/19 | 15/16 | 0.95 (0.22; 4.14) | -0.01 (-0.23; 0.22) | -127
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Lamivudine, 100 mg/day, 48 weeks | HBeAg seroconversion | 48/48 | 1/20 0/19 | 5/0 | 2.86 (0.12; 66.11) | 0.05 (-0.08; 0.18) | 20
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | HBeAg seroconversion | 48/48 | 1/20 2/19 | 5/11 | 0.48 (0.05; 4.82) | -0.06 (-0.22; 0.11) | -18
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day for 48 weeks | Lamivudine, 100 mg/day, 48 weeks | HBsAg negative | 48/48 | 1/20 0/19 | 5/0 | 2.86 (0.12; 66.11) | 0.05 (-0.08; 0.18) | 20
Adefovir dipivoxil, 10 mg/day, 48 weeks | HBsAg negative | 48/48 | 1/20 0/19 | 5/0 | 2.86 (0.12; 66.11) | 0.05 (-0.08; 0.18) | 20
Izzedine, 2004^99^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Adefovir dipivoxil, 30 mg/day, 48 weeks | Hypophosphatemia mg/dL (2.0–2.2) | 48/48 | 6/171 15/173 | 4/9 | 0.40 (0.16; 1.02) | -0.05 (-0.10; 0.00) | -19
Izzedine, 2004^99^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Adefovir dipivoxil, 30 mg/day, 48 weeks | Hypophosphatemia mg/dL (1.5–<2.0) | 48/48 | 4/171 21/173 | 2/12 | 0.19 (0.07; 0.55) | -0.10 (-0.15; -0.04) | -10
Izzedine, 2004^99^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Adefovir dipivoxil, 30 mg/day, 48 weeks | Hypophosphatemia mg/dL (1.0–1.5) | 48/48 | 1/171 5/173 | 1/3 | 0.20 (0.02; 1.71) | -0.02 (-0.05; 0.00) | -43
Izzedine, 2004^99^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Hypophosphatemia mg/dL (<1.0) | 48/48 | 0/171 1/173 | 0/1 | 0.34 (0.01; 8.22) | -0.01 (-0.02; 0.01) | -173
Izzedine, 2004^99^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Placebo, 48 weeks | Hypophosphatemia mg/dL (2.0–2.2) | 48/48 | 6/171 8/167 | 4/5 | 0.73 (0.26; 2.07) | -0.01 (-0.06; 0.03) | -78
Izzedine, 2004^99^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Placebo, 48 weeks | Hypophosphatemia mg/dL (1.5–<2.0) | 48/48 | 4/171 9/167 | 2/5 | 0.43 (0.14; 1.38) | -0.03 (-0.07; 0.01) | -33
Izzedine, 2004^99^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Placebo, 48 weeks | Hypophosphatemia mg/dL (1.0–1.5) | 48/48 | 1/171 0/167 | 1/0 | 2.93 (0.12; 71.42) | 0.01 (-0.01; 0.02) | 171
Hypophosphatemia mg/dL (<1.0) | 48/48 | 0/171 0/167 | | | 0.00 (-0.01; 0.01)
Izzedine, 2004^99^ Adefovir dipivoxil, 30 mg/day, 48 weeks | placebo, 48 weeks | Hypophosphatemia mg/dL (2.0–2.2) | 48/48 | 15/173 8/167 | 9/5 | 1.81 (0.79; 4.16) | 0.04 (-0.01; 0.09) | 26
Izzedine, 2004^99^ Adefovir dipivoxil, 30 mg/day, 48 weeks | placebo, 48 weeks | Hypophosphatemia mg/dL (1.5–<2.0) | 48/48 | 21/173 9/167 | 12/5 | 2.25 (1.06; 4.77) | 0.07 (0.01; 0.13) | 15
Izzedine, 2004^99^ Adefovir dipivoxil, 30 mg/day, 48 weeks | placebo, 48 weeks | Hypophosphatemia mg/dL (1.0–1.5) | 48/48 | 5/173 0/167 | 3/0 | 10.62 (0.59; 190.58) | 0.03 (0.00; 0.06) | 35
Hypophosphatemia mg/dL (<1.0) | 48/48 | 1/173 0/167 | 1/0 | 2.90 (0.12; 70.60) | 0.01 (-0.01; 0.02) | 173
Izzedine, 2004^99^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Adefovir dipivoxil, 30 mg/day, 48 weeks | Creatinine mg/dL (1.5–2.0) | 48/48 | 2/171 17/173 | 1/10 | 0.12 (0.03; 0.51) | -0.09 (-0.13; -0.04) | -12
Izzedine, 2004^99^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Adefovir dipivoxil, 30 mg/day, 48 weeks | Creatinine mg/dL (>2.0–3.0) | 48/48 | 0/171 0/173 | | | 0.00 (-0.01; 0.01)
Izzedine, 2004^99^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Adefovir dipivoxil, 30 mg/day, 48 weeks | Creatinine mg/dL (>3.0–6.0) | 48/48 | 0/171 0/173 | | | 0.00 (-0.01; 0.01)
Izzedine, 2004^99^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Creatinine mg/dL (>6.0)- | 48/48 | 0/171 0/173 | | | 0.00 (-0.01; 0.01)
Izzedine, 2004^99^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Placebo, 48 weeks | Creatinine mg/dL (1.5–2.0) | 48/48 | 2/171 0/167 | 1/0 | 4.88 (0.24; 100.97) | 0.01 (-0.01; 0.03) | 86
Izzedine, 2004^99^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Placebo, 48 weeks | Creatinine mg/dL (>2.0–3.0) | 48/48 | 0/171 0/167 | | | 0.00 (-0.01; 0.01)
Izzedine, 2004^99^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Placebo, 48 weeks | Creatinine mg/dL (>3.0–6.0) | 48/48 | 0/171 0/167 | | | 0.00 (-0.01; 0.01)
Creatinine mg/dL (>6.0)- | 48/48 | 0/171 0/167 | | | 0.00 (-0.01; 0.01)
Izzedine, 2004^99^ Adefovir dipivoxil, 30 mg/day, 48 weeks | Placebo, 48 weeks | Creatinine mg/dL (1.5–2.0) | 48/48 | 17/173 0/167 | 10/0 | 33.79 (2.05; 557.45) | 0.10 (0.05; 0.14) | 10
Izzedine, 2004^99^ Adefovir dipivoxil, 30 mg/day, 48 weeks | Placebo, 48 weeks | Creatinine mg/dL (>2.0–3.0) | 48/48 | 0/173 0/167 | | | 0.00 (-0.01; 0.01)
Izzedine, 2004^99^ Adefovir dipivoxil, 30 mg/day, 48 weeks | Placebo, 48 weeks | Creatinine mg/dL (>3.0–6.0) | 48/48 | 0/173 0/167 | | | 0.00 (-0.01; 0.01)
Creatinine mg/dL (>6.0)- | 48/48 | 0/173 0/167 | | | 0.00 (-0.01; 0.01)
Izzedine, 2004^99^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Placebo, 48 weeks | Hypophosphatemia mg/dL (2.0–2.2) | 48/48 | 6/171 1/167 | 4/1 | 5.86 (0.71; 48.15) | 0.03 (0.00; 0.06) | 34
Izzedine, 2004^99^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Placebo, 48 weeks | Hypophosphatemia mg/dL (1.5–<2.0) | 48/48 | 4/171 1/167 | 2/1 | 3.91 (0.44; 34.59) | 0.02 (-0.01; 0.04) | 57
Izzedine, 2004^99^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Placebo, 48 weeks | Hypophosphatemia mg/dL (1.0–1.5) | 48/48 | 0/171 0/167 | | | 0.00 (-0.01; 0.01)
Izzedine, 2004^99^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Placebo, 48 weeks | Hypophosphatemia mg/dL (<1.0) | 48/48 | 0/171 0/167 | | | 0.00 (-0.01; 0.01)
Izzedine, 2004^99^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Placebo, 48 weeks | Creatinine mg/dL (1.5–2.0) | 48/48 | 1/171 0/167 | 1/0 | 2.93 (0.12; 71.42) | 0.01 (-0.01; 0.02) | 171
Izzedine, 2004^99^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Placebo, 48 weeks | Creatinine mg/dL (>2.0–3.0) | 48/48 | 0/171 0/167 | | | 0.00 (-0.01; 0.01)
Izzedine, 2004^99^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Placebo, 48 weeks | Creatinine mg/dL (>3.0–6.0) | 48/48 | 0/171 0/167 | | | 0.00 (-0.01; 0.01)
Izzedine, 2004^99^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Creatinine mg/dL (>6.0)- | 48/48 | 0/171 0/167 | | | 0.00 (-0.01; 0.01)
Izzedine, 2004^99^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Adefovir dipivoxil, 30 mg/day, 48 weeks | Dose reduced due to an adverse event or abnormal laboratory result | 48/48 | 5/171 42/173 | 3/24 | 0.12 (0.05; 0.30) | -0.21 (-0.28; -0.14) | -5
Placebo, 48 weeks | Dose reduced due to an adverse event or abnormal laboratory result | 48/48 | 5/171 2/167 | 3/1 | 2.44 (0.48; 12.41) | 0.02 (-0.01; 0.05) | 58
Izzedine, 2004^99^ Adefovir dipivoxil, 30 mg/day, 48 weeks | Placebo, 48 weeks | Dose reduced due to an adverse event or abnormal laboratory result | 48/48 | 42/173 2/167 | 24/1 | 20.27 (4.99; 82.41) | 0.23 (0.16; 0.30) | 4
Izzedine, 2004^99^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Adefovir dipivoxil, 30 mg/day, 48 weeks | Hematuria <10 RBCs | 48/48 | 11/171 21/173 | 6/12 | 0.53 (0.26; 1.07) | -0.06 (-0.12; 0.00) | -18
Izzedine, 2004^99^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Adefovir dipivoxil, 30 mg/day, 48 weeks | Hematuria 10–100 RBCs | 48/48 | 18/171 29/173 | 11/17 | 0.63 (0.36; 1.09) | -0.06 (-0.13; 0.01) | -16
Izzedine, 2004^99^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Adefovir dipivoxil, 30 mg/day, 48 weeks | Hematuria >100 RBCs | 48/48 | 21/171 23/173 | 12/13 | 0.92 (0.53; 1.61) | -0.01 (-0.08; 0.06) | -99
Izzedine, 2004^99^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Hematuria obstructive or Rx required | 48/48 | 0/171 0/173 | | | 0.00 (-0.01; 0.01)
Izzedine, 2004^99^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Placebo, 48 weeks | Hematuria <10 RBCs | 48/48 | 11/171 11/167 | 6/7 | 0.98 (0.44; 2.19) | 0.00 (-0.05; 0.05) | -649
Izzedine, 2004^99^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Placebo, 48 weeks | Hematuria 10–100 RBCs | 48/48 | 18/171 17/167 | 11/10 | 1.03 (0.55; 1.94) | 0.00 (-0.06; 0.07) | 288
Izzedine, 2004^99^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Placebo, 48 weeks | Hematuria >100 RBCs | 48/48 | 21/171 21/167 | 12/13 | 0.98 (0.55; 1.72) | 0.00 (-0.07; 0.07) | -340
Hematuria obstructive or Rx required | 48/48 | 0/171 0/167 | | | 0.00 (-0.01; 0.01)
Izzedine, 2004^99^ Adefovir dipivoxil, 30 mg/day, 48 weeks | Placebo, 48 weeks | Hematuria <10 RBCs | 48/48 | 21/173 11/167 | 12/7 | 1.84 (0.92; 3.70) | 0.06 (-0.01; 0.12) | 18
Izzedine, 2004^99^ Adefovir dipivoxil, 30 mg/day, 48 weeks | Placebo, 48 weeks | Hematuria 10–100 RBCs | 48/48 | 29/173 17/167 | 17/10 | 1.65 (0.94; 2.88) | 0.07 (-0.01; 0.14) | 15
Izzedine, 2004^99^ Adefovir dipivoxil, 30 mg/day, 48 weeks | Placebo, 48 weeks | Hematuria >100 RBCs | 48/48 | 23/173 21/167 | 13/13 | 1.06 (0.61; 1.84) | 0.01 (-0.06; 0.08) | 139
Hematuria obstructive or Rx required | 48/48 | 0/173 0/167 | | | 0.00 (-0.01; 0.01)
Izzedine, 2004^99^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Adefovir dipivoxil, 30 mg/day, 48 weeks | Glycosuria (+1) | 48/48 | 1/171 3/173 | ½ | 0.34 (0.04; 3.21) | -0.01 (-0.03; 0.01) | -87
Izzedine, 2004^99^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Adefovir dipivoxil, 30 mg/day, 48 weeks | Glycosuria (+2) | 48/48 | 1/171 3/173 | 1/2 | 0.34 (0.04; 3.21) | -0.01 (-0.03; 0.01) | -87
Izzedine, 2004^99^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Adefovir dipivoxil, 30 mg/day, 48 weeks | Glycosuria (+3) | 48/48 | 1/171 2/173 | 1/1 | 0.51 (0.05; 5.53) | -0.01 (-0.03; 0.01) | -175
Izzedine, 2004^99^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Glycosuria (+4) | 48/48 | 0/171 0/173 | | | 0.00 (-0.01; 0.01)
Izzedine, 2004^99^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Placebo, 48 weeks | Glycosuria (+1) | 48/48 | 1/171 5/167 | 1/3 | 0.20 (0.02; 1.65) | -0.02 (-0.05; 0.00) | -42
Izzedine, 2004^99^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Placebo, 48 weeks | Glycosuria (+2) | 48/48 | 1/171 3/167 | 1/2 | 0.33 (0.03; 3.10) | -0.01 (-0.04; 0.01) | -83
Izzedine, 2004^99^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Placebo, 48 weeks | Glycosuria (+3) | 48/48 | 1/171 5/167 | 1/3 | 0.20 (0.02; 1.65) | -0.02 (-0.05; 0.00) | -42
Glycosuria (+4) | 48/48 | 0/171 0/167 | | | 0.00 (-0.01; 0.01)
Izzedine, 2004^99^ Adefovir dipivoxil, 30 mg/day, 48 weeks | Placebo, 48 weeks | Glycosuria (+1) | 48/48 | 3/173 5/167 | 2/3 | 0.58 (0.14; 2.39) | -0.01 (-0.04; 0.02) | -79
Izzedine, 2004^99^ Adefovir dipivoxil, 30 mg/day, 48 weeks | Placebo, 48 weeks | Glycosuria (+2) | 48/48 | 3/173 3/167 | 2/2 | 0.97 (0.20; 4.72) | 0.00 (-0.03; 0.03) | -1605
Izzedine, 2004^99^ Adefovir dipivoxil, 30 mg/day, 48 weeks | Placebo, 48 weeks | Glycosuria (+3) | 48/48 | 2/173 5/167 | 1/3 | 0.39 (0.08; 1.96) | -0.02 (-0.05; 0.01) | -54
Glycosuria (+4) | 48/48 | 0/173 0/167 | | | 0.00 (-0.01; 0.01)
Izzedine, 2004^99^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Adefovir dipivoxil, 30 mg/day, 48 weeks | Proteinuria mg/dL (<100) | 48/48 | 24/171 38/173 | 14/22 | 0.64 (0.40; 1.02) | -0.08 (-0.16; 0.00) | -13
Izzedine, 2004^99^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Adefovir dipivoxil, 30 mg/day, 48 weeks | Proteinuria mg/dL (100–1000) | 48/48 | 10/171 23/173 | 6/13 | 0.44 (0.22; 0.90) | -0.07 (-0.14; -0.01) | -13
Izzedine, 2004^99^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Adefovir dipivoxil, 30 mg/day, 48 weeks | Proteinuria mg/dL (>1000) | 48/48 | 0/171 0/173 | | | 0.00 (-0.01; 0.01)
Izzedine, 2004^99^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Proteinuria mg/dL (nephrotic syndrome) | 48/48 | 0/171 0/173 | | | 0.00 (-0.01; 0.01)
Izzedine, 2004^99^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Placebo, 48 weeks | Proteinuria mg/dL (<100) | 48/48 | 24/171 17/167 | 14/10 | 1.38 (0.77; 2.47) | 0.04 (-0.03; 0.11) | 26
Izzedine, 2004^99^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Placebo, 48 weeks | Proteinuria mg/dL (100–1000) | 48/48 | 10/171 11/167 | 6/7 | 0.89 (0.39; 2.03) | -0.01 (-0.06; 0.04) | -135
Izzedine, 2004^99^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Placebo, 48 weeks | Proteinuria mg/dL (>1000) | 48/48 | 0/171 0/167 | | | 0.00 (-0.01; 0.01)
Proteinuria mg/dL (nephrotic syndrome) | 48/48 | 0/171 0/167 | | | 0.00 (-0.01; 0.01)
Izzedine, 2004^99^ Adefovir dipivoxil, 30 mg/day, 48 weeks | Placebo, 48 weeks | Proteinuria mg/dL (<100) | 48/48 | 38/173 17/167 | 22/10 | 2.16 (1.27; 3.67) | 0.12 (0.04; 0.19) | 8
Izzedine, 2004^99^ Adefovir dipivoxil, 30 mg/day, 48 weeks | Placebo, 48 weeks | Proteinuria mg/dL (100–1000) | 48/48 | 23/173 11/167 | 13/7 | 2.02 (1.02; 4.01) | 0.07 (0.00; 0.13) | 15
Izzedine, 2004^99^ Adefovir dipivoxil, 30 mg/day, 48 weeks | Placebo, 48 weeks | Proteinuria mg/dL (>1000) | 48/48 | 0/173 0/167 | | | 0.00 (-0.01; 0.01)
Proteinuria mg/dL (nephrotic syndrome) | 48/48 | 0/173 0/167 | | | 0.00 (-0.01; 0.01)
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Placebo after 48 weeks of adefovir therapy, 96 weeks | Normalization of ALT | 96/96 | 47/80 12/40 | 59/30 | 1.96 (1.18; 3.25) | 0.29 (0.11; 0.47) | 3
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Adefovir dipivoxil, 10mg daily after 48 weeks of placebo therapy, 96 weeks | Normalization of ALT | 96/96 | 47/80 40/60 | 59/67 | 0.88 (0.68; 1.14) | -0.08 (-0.24; 0.08) | -13
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Placebo after 48 weeks of adefovir therapy, 96 weeks | Normalization of ALT | 114/96 | 43/80 12/40 | 54/30 | 1.79 (1.07; 3.00) | 0.24 (0.06; 0.42) | 4
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Adefovir dipivoxil, 10 mg daily after 48 weeks of placebo therapy, 96 weeks | Normalization of ALT | 114/96 | 43/80 40/60 | 54/67 | 0.81 (0.61; 1.06) | -0.13 (-0.29; 0.03) | -8
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Placebo after 48 weeks of adefovir therapy, 96 weeks | Any adverse events | 96/96 | 58/80 32/40 | 72/80 | 0.91 (0.74; 1.11) | -0.08 (-0.23; 0.08) | -13
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Adefovir dipivoxil, 10mg daily after 48 weeks of placebo therapy, 96 weeks | Any adverse events | 96/96 | 58/80 41/60 | 72/68 | 1.06 (0.85; 1.32) | 0.04 (-0.11; 0.19) | 24
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Placebo after 48 weeks of adefovir therapy, 96 weeks | Any adverse events | 114/96 | 60/80 32/40 | 75/80 | 0.94 (0.77; 1.15) | -0.05 (-0.21; 0.11) | -20
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Adefovir dipivoxil, 10mg daily after 48 weeks of placebo therapy, 96 weeks | Any adverse events | 114/96 | 60/80 41/60 | 75/68 | 1.10 (0.89; 1.36) | 0.07 (-0.08; 0.22) | 15
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Placebo after 48 weeks of adefovir therapy, 96 weeks | Headache | 96/96 | 12/80 4/40 | 15/10 | 1.50 (0.52; 4.36) | 0.05 (-0.07; 0.17) | 20
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Placebo after 48 weeks of adefovir therapy, 96 weeks | Abdominal pain | 96/96 | 16/80 7/40 | 20/18 | 1.14 (0.51; 2.55) | 0.03 (-0.12; 0.17) | 40
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Placebo after 48 weeks of adefovir therapy, 96 weeks | Asthenia | 96/96 | 8/80 6/40 | 10/15 | 0.67 (0.25; 1.79) | -0.05 (-0.18; 0.08) | -20
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Placebo after 48 weeks of adefovir therapy, 96 weeks | Flu-like syndrome | 96/96 | 6/80 4/40 | 8/10 | 0.75 (0.22; 2.51) | -0.03 (-0.13; 0.08) | -40
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Placebo after 48 weeks of adefovir therapy, 96 weeks | Back pain | 96/96 | 4/80 5/40 | 5/12 | 0.40 (0.11; 1.41) | -0.08 (-0.19; 0.04) | -13
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Placebo after 48 weeks of adefovir therapy, 96 weeks | Pain | 96/96 | 4/80 2/40 | 5/5 | 1.00 (0.19; 5.23) | 0.00 (-0.08; 0.08)
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Placebo after 48 weeks of adefovir therapy, 96 weeks | Accidental injury | 96/96 | 4/80 2/40 | 5/5 | 1.00 (0.19; 5.23) | 0.00 (-0.08; 0.08)
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Adefovir dipivoxil, 10mg daily after 48 weeks of placebo therapy, 96 weeks | Headache | 96/96 | 12/80 5/60 | 15/8 | 1.80 (0.67; 4.84) | 0.07 (-0.04; 0.17) | 15
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Adefovir dipivoxil, 10mg daily after 48 weeks of placebo therapy, 96 weeks | Abdominal pain | 96/96 | 16/80 5/60 | 20/8 | 2.40 (0.93; 6.19) | 0.12 (0.00; 0.23) | 9
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Adefovir dipivoxil, 10mg daily after 48 weeks of placebo therapy, 96 weeks | Asthenia | 96/96 | 8/80 3/60 | 10/5 | 2.00 (0.55; 7.22) | 0.05 (-0.04; 0.14) | 20
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Adefovir dipivoxil, 10mg daily after 48 weeks of placebo therapy, 96 weeks | Flu-like syndrome | 96/96 | 6/80 5/60 | 8/8 | 0.90 (0.29; 2.81) | -0.01 (-0.10; 0.08) | -120
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Adefovir dipivoxil, 10mg daily after 48 weeks of placebo therapy, 96 weeks | Back pain | 96/96 | 4/80 3/60 | 5/5 | 1.00 (0.23; 4.30) | 0.00 (-0.07; 0.07)
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Adefovir dipivoxil, 10mg daily after 48 weeks of placebo therapy, 96 weeks | Pain | 96/96 | 4/80 4/60 | 5/7 | 0.75 (0.20; 2.88) | -0.02 (-0.10; 0.06) | -60
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Accidental injury | 96/96 | 4/80 2/60 | 5/3 | 1.50 (0.28; 7.92) | 0.02 (-0.05; 0.08) | 60
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Placebo after 48 weeks of adefovir therapy, 96 weeks | Headache | 114/96 | 19/80 4/40 | 24/10 | 2.38 (0.87; 6.52) | 0.14 (0.01; 0.27) | 7
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Placebo after 48 weeks of adefovir therapy, 96 weeks | Abdominal pain | 114/96 | 20/80 7/40 | 25/18 | 1.43 (0.66; 3.09) | 0.08 (-0.08; 0.23) | 13
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Placebo after 48 weeks of adefovir therapy, 96 weeks | Asthenia | 114/96 | 15/80 6/40 | 19/15 | 1.25 (0.53; 2.98) | 0.04 (-0.10; 0.18) | 27
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Placebo after 48 weeks of adefovir therapy, 96 weeks | Flu-like syndrome | 114/96 | 14/80 4/40 | 18/10 | 1.75 (0.62; 4.97) | 0.08 (-0.05; 0.20) | 13
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Placebo after 48 weeks of adefovir therapy, 96 weeks | Back pain | 114/96 | 9/80 5/40 | 11/12 | 0.90 (0.32; 2.51) | -0.01 (-0.14; 0.11) | -80
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Placebo after 48 weeks of adefovir therapy, 96 weeks | Pain | 114/96 | 12/80 2/40 | 15/5 | 3.00 (0.71; 12.76) | 0.10 (0.00; 0.20) | 10
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Accidental injury | 114/96 | 8/80 2/40 | 10/5 | 2.00 (0.45; 8.98) | 0.05 (-0.04; 0.14) | 20
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Adefovir dipivoxil, 10mg daily after 48 weeks of placebo therapy, 96 weeks | Headache | 114/96 | 19/80 5/60 | 24/8 | 2.85 (1.13; 7.20) | 0.15 (0.04; 0.27) | 6
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Adefovir dipivoxil, 10mg daily after 48 weeks of placebo therapy, 96 weeks | Abdominal pain | 114/96 | 20/80 5/60 | 25/8 | 3.00 (1.19; 7.54) | 0.17 (0.05; 0.28) | 6
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Adefovir dipivoxil, 10mg daily after 48 weeks of placebo therapy, 96 weeks | Asthenia | 114/96 | 15/80 3/60 | 19/5 | 3.75 (1.14; 12.37) | 0.14 (0.04; 0.24) | 7
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Adefovir dipivoxil, 10mg daily after 48 weeks of placebo therapy, 96 weeks | Flu-like syndrome | 114/96 | 14/80 5/60 | 18/8 | 2.10 (0.80; 5.51) | 0.09 (-0.02; 0.20) | 11
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Adefovir dipivoxil, 10mg daily after 48 weeks of placebo therapy, 96 weeks | Back pain | 114/96 | 9/80 3/60 | 11/5 | 2.25 (0.64; 7.96) | 0.06 (-0.03; 0.15) | 16
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Adefovir dipivoxil, 10mg daily after 48 weeks of placebo therapy, 96 weeks | Pain | 114/96 | 12/80 4/60 | 15/7 | 2.25 (0.76; 6.63) | 0.08 (-0.02; 0.18) | 12
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Accidental injury | 114/96 | 8/80 2/60 | 10/3 | 3.00 (0.66; 13.62) | 0.07 (-0.01; 0.15) | 15
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Placebo after 48 weeks of adefovir therapy, 96 weeks | Diarrhea | 96/96 | 6/80 4/40 | 8/10 | 0.75 (0.22; 2.51) | -0.03 (-0.13; 0.08) | -40
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Dyspepsia | 96/96 | 4/80 5/40 | 5/12 | 0.40 (0.11; 1.41) | -0.08 (-0.19; 0.04) | -13
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Adefovir dipivoxil, 10mg daily after 48 weeks of placebo therapy, 96 weeks | Diarrhea | 96/96 | 6/80 1/60 | 8/2 | 4.50 (0.56; 36.40) | 0.06 (-0.01; 0.12) | 17
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Dyspepsia | 96/96 | 4/80 1/60 | 5/2 | 3.00 (0.34; 26.16) | 0.03 (-0.02; 0.09) | 30
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Placebo after 48 weeks of adefovir therapy, 96 weeks | Diarrhea | 114/96 | 6/80 4/40 | 8/10 | 0.75 (0.22; 2.51) | -0.03 (-0.13; 0.08) | -40
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Dyspepsia | 114/96 | 7/80 5/40 | 9/12 | 0.70 (0.24; 2.07) | -0.04 (-0.16; 0.08) | -27
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Adefovir dipivoxil, 10mg daily after 48 weeks of placebo therapy, 96 weeks | Diarrhea | 114/96 | 6/80 1/60 | 8/2 | 4.50 (0.56; 36.40) | 0.06 (-0.01; 0.12) | 17
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Dyspepsia | 114/96 | 7/80 1/60 | 9/2 | 5.25 (0.66; 41.54) | 0.07 (0.00; 0.14) | 14
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Placebo after 48 weeks of adefovir therapy, 96 weeks | Pharyngitis | 96/96 | 14/80 8/40 | 18/20 | 0.88 (0.40; 1.91) | -0.03 (-0.17; 0.12) | -40
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Placebo after 48 weeks of adefovir therapy, 96 weeks | Increased cough | 96/96 | 3/80 4/40 | 4/10 | 0.38 (0.09; 1.60) | -0.06 (-0.16; 0.04) | -16
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Placebo after 48 weeks of adefovir therapy, 96 weeks | Bronchitis | 96/96 | 2/80 1/40 | 2/2 | 1.00 (0.09; 10.70) | 0.00 (-0.06; 0.06)
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Placebo after 48 weeks of adefovir therapy, 96 weeks | Increased Alanine aminotransferase levels | 96/96 | 2/80 6/40 | 2/15 | 0.17 (0.04; 0.79) | -0.13 (-0.24; -0.01) | -8
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Placebo after 48 weeks of adefovir therapy, 96 weeks | Arthralgia | 96/96 | 6/80 5/40 | 8/12 | 0.60 (0.19; 1.85) | -0.05 (-0.17; 0.07) | -20
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Placebo after 48 weeks of adefovir therapy, 96 weeks | Increased creatinine levels | 96/96 | 2/80 0/40 | 2/0 | 2.53 (0.12; 51.50) | 0.03 (-0.03; 0.08) | 40
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Placebo after 48 weeks of adefovir therapy, 96 weeks | Hematuria | 96/96 | 1/80 0/40 | 1/0 | 1.52 (0.06; 36.46) | 0.01 (-0.03; 0.06) | 80
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Placebo after 48 weeks of adefovir therapy, 96 weeks | Kidney calculus | 96/96 | 0/80 0/40 | | | 0.00 (-0.04; 0.04)
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Kidney pain | 96/96 | 0/80 0/40 | | | 0.00 (-0.04; 0.04)
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Adefovir dipivoxil, 10mg daily after 48 weeks of placebo therapy, 96 weeks | Pharyngitis | 96/96 | 14/80 8/60 | 18/13 | 1.31 (0.59; 2.93) | 0.04 (-0.08; 0.16) | 24
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Adefovir dipivoxil, 10mg daily after 48 weeks of placebo therapy, 96 weeks | Increased cough | 96/96 | 3/80 2/60 | 4/3 | 1.13 (0.19; 6.52) | 0.00 (-0.06; 0.07) | 240
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Adefovir dipivoxil, 10mg daily after 48 weeks of placebo therapy, 96 weeks | Bronchitis | 96/96 | 2/80 1/60 | 2/2 | 1.50 (0.14; 16.16) | 0.01 (-0.04; 0.06) | 120
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Adefovir dipivoxil, 10mg daily after 48 weeks of placebo therapy, 96 weeks | Increased Alanine aminotransferase levels | 96/96 | 2/80 1/60 | 2/2 | 1.50 (0.14; 16.16) | 0.01 (-0.04; 0.06) | 120
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Adefovir dipivoxil, 10mg daily after 48 weeks of placebo therapy, 96 weeks | Arthralgia | 96/96 | 6/80 1/60 | 8/2 | 4.50 (0.56; 36.40) | 0.06 (-0.01; 0.12) | 17
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Adefovir dipivoxil, 10mg daily after 48 weeks of placebo therapy, 96 weeks | Increased creatinine levels | 96/96 | 2/80 0/60 | 2/0 | 3.77 (0.18; 77.01) | 0.03 (-0.02; 0.07) | 40
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Adefovir dipivoxil, 10mg daily after 48 weeks of placebo therapy, 96 weeks | Hematuria | 96/96 | 1/801/60 | 1/2 | 0.75 (0.05; 11.75) | 0.00 (-0.04; 0.04) | -240
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Adefovir dipivoxil, 10mg daily after 48 weeks of placebo therapy, 96 weeks | Kidney calculus | 96/96 | 0/80 1/60 | 0/2 | 0.25 (0.01; 6.06) | -0.02 (-0.06; 0.03) | -60
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Kidney pain | 96/96 | 0/80 1/60 | 0/2 | 0.25 (0.01; 6.06) | -0.02 (-0.06; 0.03) | -60
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Placebo after 48 weeks of adefovir therapy, 96 weeks | Pharyngitis | 114/96 | 25/80 8/40 | 31/20 | 1.56 (0.78; 3.15) | 0.11 (-0.05; 0.27) | 9
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Placebo after 48 weeks of adefovir therapy, 96 weeks | Increased cough | 114/96 | 7/80 4/40 | 9/10 | 0.88 (0.27; 2.81) | -0.01 (-0.12; 0.10) | -80
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Placebo after 48 weeks of adefovir therapy, 96 weeks | Bronchitis | 114/96 | 9/80 1/40 | 11/2 | 4.50 (0.59; 34.29) | 0.09 (0.00; 0.17) | 11
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Placebo after 48 weeks of adefovir therapy, 96 weeks | Increased alanine aminotransferase levels | 114/96 | 3/80 6/40 | 4/15 | 0.25 (0.07; 0.95) | -0.11 (-0.23; 0.01) | -9
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Placebo after 48 weeks of adefovir therapy, 96 weeks | Arthralgia | 114/96 | 6/80 5/40 | 8/12 | 0.60 (0.19; 1.85) | -0.05 (-0.17; 0.07) | -20
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Placebo after 48 weeks of adefovir therapy, 96 weeks | Increased creatinine levels | 114/96 | 3/80 0/40 | 4/0 | 3.54 (0.19; 66.97) | 0.04 (-0.02; 0.09) | 27
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Placebo after 48 weeks of adefovir therapy, 96 weeks | Hematuria | 114/96 | 2/80 0/40 | 2/0 | 2.53 (0.12; 51.50) | 0.03 (-0.03; 0.08) | 40
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Placebo after 48 weeks of adefovir therapy, 96 weeks | Kidney calculus | 114/96 | 1/80 0/40 | 1/0 | 1.52 (0.06; 36.46) | 0.01 (-0.03; 0.06) | 80
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Kidney pain | 114/96 | 4/80 0/40 | 5/0 | 4.56 (0.25; 82.59) | 0.05 (-0.01; 0.11) | 20
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Adefovir dipivoxil, 10mg daily after 48 weeks of placebo therapy, 96 weeks | Pharyngitis | 114/96 | 25/80 8/60 | 31/13 | 2.34 (1.14; 4.83) | 0.18 (0.05; 0.31) | 6
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Adefovir dipivoxil, 10mg daily after 48 weeks of placebo therapy, 96 weeks | Increased cough | 114/96 | 7/80 2/60 | 9/3 | 2.63 (0.57; 12.19) | 0.05 (-0.02; 0.13) | 18
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Adefovir dipivoxil, 10mg daily after 48 weeks of placebo therapy, 96 weeks | Bronchitis | 114/96 | 9/80 1/60 | 11/2 | 6.75 (0.88; 51.84) | 0.10 (0.02; 0.17) | 10
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Adefovir dipivoxil, 10mg daily after 48 weeks of placebo therapy, 96 weeks | Increased ALT levels | 114/96 | 3/80 1/60 | 4/2 | 2.25 (0.24; 21.10) | 0.02 (-0.03; 0.07) | 48
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Adefovir dipivoxil, 10mg daily after 48 weeks of placebo therapy, 96 weeks | Arthralgia | 114/96 | 6/80 1/60 | 8/2 | 4.50 (0.56; 36.40) | 0.06 (-0.01; 0.12) | 17
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Adefovir dipivoxil, 10mg daily after 48 weeks of placebo therapy, 96 weeks | Increased creatinine levels | 114/96 | 3/80 0/60 | 4/0 | 5.27 (0.28; 100.17) | 0.04 (-0.01; 0.09) | 27
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Adefovir dipivoxil, 10mg daily after 48 weeks of placebo therapy, 96 weeks | Hematuria | 114/96 | 2/80 1/60 | 2/2 | 1.50 (0.14; 16.16) | 0.01 (-0.04; 0.06) | 120
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Adefovir dipivoxil, 10mg daily after 48 weeks of placebo therapy, 96 weeks | Kidney calculus | 114/96 | 1/80 1/60 | 1/2 | 0.75 (0.05; 11.75) | 0.00 (-0.04; 0.04) | -240
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Kidney pain | 114/96 | 4/80 1/60 | 5/2 | 3.00 (0.34; 26.16) | 0.03 (-0.02; 0.09) | 30
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Placebo after 48 weeks of adefovir therapy, 96 weeks | Improvement in histological scores | 96/96 | 17/80 4/40 | 21/10 | 2.13 (0.77; 5.90) | 0.11 (-0.02; 0.24) | 9
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Adefovir dipivoxil, 10mg daily after 48 weeks of placebo therapy, 96 weeks | Improvement in histological scores | 96/96 | 17/80 14/60 | 21/23 | 0.91 (0.49; 1.70) | -0.02 (-0.16; 0.12) | -48
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Placebo after 48 weeks of adefovir therapy, 96 weeks | Serum HBV DNA level <1000 log copies/ml | 96/96 | 50/80 3/40 | 62/8 | 8.33 (2.77; 25.07) | 0.55 (0.42; 0.68) | 2
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Adefovir dipivoxil, 10mg daily after 48 weeks of placebo therapy, 96 weeks | Serum HBV DNA level <1000 log copies/ml | 96/96 | 50/80 37/60 | 62/62 | 1.01 (0.78; 1.32) | 0.01 (-0.15; 0.17) | 120
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Placebo after 48 weeks of adefovir therapy, 96 weeks | Serum HBV DNA level <1000 log copies/ml | 114/96 | 53/80 3/40 | 66/8 | 8.83 (2.94; 26.52) | 0.59 (0.46; 0.72) | 2
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Adefovir dipivoxil, 10mg daily after 48 weeks of placebo therapy, 96 weeks | Serum HBV DNA level <1000 log copies/ml | 114/96 | 53/80 37/60 | 66/62 | 1.07 (0.83; 1.38) | 0.05 (-0.12; 0.21) | 22
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Placebo after 48 weeks of adefovir therapy, 96 weeks | HBsAg seroconversion | 96/96 | 1/80 0/40 | 1/0 | 1.52 (0.06; 36.46) | 0.01 (-0.03; 0.06) | 80
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Adefovir dipivoxil, 10mg daily after 48 weeks of placebo therapy, 96 weeks | HBsAg seroconversion | 96/96 | 1/80 1/60 | 1/2 | 0.75 (0.05; 11.75) | 0.00 (-0.04; 0.04) | -240
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Placebo after 48 weeks of adefovir therapy, 96 weeks | conserved site mutation (rtN236T) | 114/96 | 4/80 0/40 | 5/0 | 4.56 (0.25; 82.59) | 0.05 (-0.01; 0.11) | 20
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Adefovir dipivoxil, 10mg daily after 48 weeks of placebo therapy, 96 weeks | Conserved site mutation (rtN236T) | 114/96 | 4/80 0/60 | 5/0 | 6.78 (0.37; 123.52) | 0.05 (0.00; 0.10) | 20
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10mg daily, continued adefovir therapy of the previous treatment for 48 weeks, total 96 weeks | Placebo after 48 weeks of adefovir therapy, 96 weeks | conserved site substitution mutation (rtA181V) in the B domain of HBV polymerase | 114/96 | 3/80 0/40 | 4/0 | 3.54 (0.19; 66.97) | 0.04 (-0.02; 0.09) | 27
Adefovir dipivoxil, 10mg daily after 48 weeks of placebo therapy, 96 weeks | conserved site substitution mutation (rtA181V) in the B domain of HBV polymerase | 114/96 | 3/80 0/60 | 4/0 | 5.27 (0.28; 100.17) | 0.04 (-0.01; 0.09) | 27
Zeng, 2006^40^ Adefovir dipivoxil, 10 mg/day, 12 weeks Adefovir dipivoxil, 10 mg/day then placebo | placebo for 12 weeks followed by Adefovir dipivoxil for 40 weeks | ALT normalization | 39794 | 92/240 15/120 | 38/12 | 3.07 (1.86; 5.06) | 0.26 (0.17; 0.34) | 4
Placebo, 12 weeks | ALT normalization | 39794 | 48/120 15/120 | 40/12 | 3.20 (1.90; 5.39) | 0.28 (0.17; 0.38) | 4
Zeng, 2006^40^ Adefovir dipivoxil, 10 mg/day after placebo for 12 weeks, duration of Adefovir dipivoxil 40 weeks, total 52 weeks | Placebo, placebo for 12 weeks after Adefovir dipivoxil for 40 weeks, 52 weeks | ALT normalization | 52/52 | 74/120 23/120 | 62/19 | 3.22 (2.17; 4.77) | 0.43 (0.31; 0.54) | 2
Zeng, 2006^40^ Adefovir dipivoxil, 10 mg/day, total duration of Adefovir dipivoxil 52 weeks | Placebo for 12 weeks after Adefovir dipivoxil for 40 weeks, 52 weeks | ALT normalization | 52/52 | 176/240 23/120 | 73/19 | 3.83 (2.63; 5.57) | 0.54 (0.45; 0.63) | 2
Zeng, 2006^40^ Adefovir dipivoxil, 10mg/day after placebo for 12 weeks, duration of Adefovir dipivoxil 40 weeks, total 52 weeks | Adefovir dipivoxil, 10 mg/day, total duration of Adefovir dipivoxil 52 weeks | ALT normalization | 52/52 | 74/120 176/240 | 62/73 | 0.84 (0.72; 0.99) | -0.12 (-0.22; -0.01) | -9
Zeng, 2006^40^ Adefovir dipivoxil, 10mg/day, 12 weeks | Placebo, 12 weeks followed by adefovir | ALT increase to >5 ULN and 2 baseline (for first 12 weeks) or 2 nadir (for subsequent intervals) | 12/12 | 1/240 5/120 | 0/4 | 0.10 (0.01; 0.85) | -0.04 (-0.07; 0.00) | -27
Placebo, 12 weeks | 12/12 | 1/120 5/120 | 1/4 | 0.20 (0.02; 1.69) | -0.03 (-0.07; 0.01) | -30
Zeng, 2006^40^ Adefovir dipivoxil, 10mg/day after placebo for 12 weeks, duration of Adefovir dipivoxil 40 weeks, total 52 weeks | Placebo for 12 weeks after Adefovir dipivoxil for 40 weeks, total 52 weeks | ALT increase to >5 ULN and 2 baseline (for first 12 weeks) or 2 nadir (for subsequent intervals). | 52/52 | 0/120 34/120 | 0/28 | 0.01 (0.00; 0.23) | -0.28 (-0.36; -0.20) | -4
Zeng, 2006^40^ Adefovir dipivoxil, 10mg/day, 52 weeks | Placebo for 12 weeks after Adefovir dipivoxil for 40 weeks, total 52 weeks | | 52/52 | 1/240 34/120 | 0/28 | 0.01 (0.00; 0.11) | -0.28 (-0.36; -0.20) | -4
Zeng, 2006^40^ Adefovir dipivoxil, 10mg/day after placebo for 12 weeks, duration of Adefovir dipivoxil 40 weeks, total 52 weeks | Adefovir dipivoxil, 10 mg/day, 52 weeks | ALT increase to > 5 ULN and 2 baseline (for first 12 weeks) or 2 nadir (for subsequent intervals) | 52/52 | 0/120 1/240 | | 0.66 (0.03; 16.18) | 0.00 (-0.02; 0.01) | -240
Zeng, 2006^40^ Adefovir dipivoxil, 10 mg/day, 12 weeks | Placebo, 12 weeks | ALT normalization | 52/52 | 140/360 15/120 | 39/12 | 3.11 (1.90; 5.08) | 0.26 (0.19; 0.34) | 4
Zeng, 2006^40^ Adefovir dipivoxil, 10 mg/day, 12 weeks | Placebo, 12 weeks | Discontinuation due to adverse effects | 39794 | 2/240 0/120 | 1/0 | 2.51 (0.12; 51.88) | 0.01 (-0.01; 0.03) | 120
Discontinuation due to adverse effects | 39794 | 1/120 0/120 | 1/0 | 3.00 (0.12; 72.91) | 0.01 (-0.01; 0.03) | 120
Zeng, 2006^40^ Adefovir dipivoxil, 10mg/day after placebo for 12 weeks, duration of Adefovir dipivoxil 40 weeks, total 52 weeks | Placebo for 12 weeks after Adefovir dipivoxil for 40 weeks, total 52 weeks | Reactivation of hepatitis B | 52/52 | 1/120 11/120 | 1/9 | 0.09 (0.01; 0.69) | -0.08 (-0.14; -0.03) | -12
Zeng, 2006^40^ Adefovir dipivoxil, 10mg/day after placebo for 12 weeks, duration of Adefovir dipivoxil 40 weeks, total 52 weeks | Placebo for 12 weeks after Adefovir dipivoxil for 40 weeks, total 52 weeks | Upper respiratory tract infection | 52/52 | 10/120 9/120 | 8/8 | 1.11 (0.47; 2.64) | 0.01 (-0.06; 0.08) | 120
Zeng, 2006^40^ Adefovir dipivoxil, 10mg/day after placebo for 12 weeks, duration of Adefovir dipivoxil 40 weeks, total 52 weeks | Placebo for 12 weeks after Adefovir dipivoxil for 40 weeks, total 52 weeks | Fatigue | 52/52 | 7/120 8/120 | 6/7 | 0.88 (0.33; 2.34) | -0.01 (-0.07; 0.05) | -120
Nasopharyngitis | 52/52 | 6/120 2/120 | 5/2 | 3.00 (0.62; 14.57) | 0.03 (-0.01; 0.08) | 30
Zeng, 2006^40^ Adefovir dipivoxil, 10mg/day, 52 weeks | Placebo for 12 weeks after Adefovir dipivoxil for 40 weeks, total 52 weeks | Reactivation of hepatitis B | 52/52 | 1/240 11/120 | 0/9 | 0.05 (0.01; 0.35) | -0.09 (-0.14; -0.04) | -11
Zeng, 2006^40^ Adefovir dipivoxil, 10mg/day, 52 weeks | Placebo for 12 weeks after Adefovir dipivoxil for 40 weeks, total 52 weeks | Upper respiratory tract infection | 52/52 | 20/240 9/120 | 8/8 | 1.11 (0.52; 2.37) | 0.01 (-0.05; 0.07) | 120
Zeng, 2006^40^ Adefovir dipivoxil, 10mg/day, 52 weeks | Placebo for 12 weeks after Adefovir dipivoxil for 40 weeks, total 52 weeks | Fatigue | 52/52 | 6/240 8/120 | 2/7 | 0.38 (0.13; 1.06) | -0.04 (-0.09; 0.01) | -24
Nasopharyngitis | 52/52 | 11/240 2/120 | 5/2 | 2.75 (0.62; 12.21) | 0.03 (-0.01; 0.06) | 34
Zeng, 2006^40^ Adefovir dipivoxil, 10 mg/day after placebo for 12 weeks, duration of Adefovir dipivoxil 40 weeks, total 52 weeks | Adefovir dipivoxil, 10mg/day, 52 weeks | Reactivation of Hepatitis B | 52/52 | 1/120 1/240 | 1/0 | 2.00 (0.13; 31.70) | 0.00 (-0.01; 0.02) | 240
Zeng, 2006^40^ Adefovir dipivoxil, 10 mg/day after placebo for 12 weeks, duration of Adefovir dipivoxil 40 weeks, total 52 weeks | Adefovir dipivoxil, 10mg/day, 52 weeks | Upper respiratory tract infection | 52/52 | 10/120 20/240 | 8/8 | 1.00 (0.48; 2.07) | 0.00 (-0.06; 0.06)
Zeng, 2006^40^ Adefovir dipivoxil, 10 mg/day after placebo for 12 weeks, duration of Adefovir dipivoxil 40 weeks, total 52 weeks | Adefovir dipivoxil, 10mg/day, 52 weeks | Fatigue | 52/52 | 7/120 6/240 | 6/2 | 2.33 (0.80; 6.79) | 0.03 (-0.01; 0.08) | 30
Zeng, 2006^40^ Adefovir dipivoxil, 10 mg/day after placebo for 12 weeks, duration of Adefovir dipivoxil 40 weeks, total 52 weeks | Nasopharyngitis | 52/52 | 6/120 11/240 | 5/5 | 1.09 (0.41; 2.88) | 0.00 (-0.04; 0.05) | 240
Placebo for 12 weeks after Adefovir dipivoxil for 40 weeks, total 52 weeks | Incidence of elevation of serum ALT to >5 times the ULN | 52/52 | 46/120 66/120 | 38/55 | 0.70 (0.53; 0.92) | -0.17 (-0.29; -0.04) | -6
Zeng, 2006^40^ Adefovir dipivoxil, 10 mg/day, 52 weeks | Placebo for 12 weeks after Adefovir dipivoxil for 40 weeks, total 52 weeks | Incidence of elevation of serum ALT to >5 times the ULN | 52/52 | 51/240 66/120 | 21/55 | 0.39 (0.29; 0.52) | -0.34 (-0.44; -0.23) | -3
Zeng, 2006^40^ Adefovir dipivoxil, 10 mg/day after placebo for 12 weeks, duration of Adefovir dipivoxil 40 weeks, total 52 weeks | Adefovir dipivoxil, 10 mg/day, 52 weeks | Incidence of elevation of serum ALT >5 times the ULN | 52/52 | 46/120 51/240 | 38/21 | 1.80 (1.29; 2.52) | 0.17 (0.07; 0.27) | 6
Zeng, 2006^40^ Adefovir dipivoxil, 10 mg/day, 12 weeks | placebo for 12 weeks | HBV DNA <105 copies/mL | 39794 | 113/240 4/120 | 47/3 | 14.13 (5.34; 37.37) | 0.44 (0.37; 0.51) | 2
HBV DNA < 300 copies/mL | 39794 | 11/240 0/120 | 5/0 | 11.55 (0.69; 194.31) | 0.05 (0.02; 0.08) | 22
Zeng, 2006^40^ Adefovir dipivoxil, 10mg/day after placebo for 12 weeks, duration of Adefovir dipivoxil 40 weeks, total 52 weeks | Placebo for 12 weeks after Adefovir dipivoxil for 40 weeks, total 52 weeks | HBV DNA <105 copies/mL | 52/52 | 81/120 13/120 | 68/11 | 6.23 (3.67; 10.57) | 0.57 (0.47; 0.67) | 2
Zeng, 2006^40^ Adefovir dipivoxil, 10mg/day, 52 weeks | Placebo for 12 weeks after Adefovir dipivoxil for 40 weeks, total 52 weeks | HBV DNA <105 copies/mL | 52/52 | 155/240 13/120 | 65/11 | 5.96 (3.54; 10.05) | 0.54 (0.46; 0.62) | 2
Zeng, 2006^40^ Adefovir dipivoxil, 10mg/day after placebo for 12 weeks, duration of Adefovir dipivoxil 40 weeks, total 52 weeks | Adefovir dipivoxil, 10 mg/day, 52 weeks | HBV DNA <105 copies/mL | 52/52 | 81/120 155/240 | 68/65 | 1.05 (0.89; 1.22) | 0.03 (-0.07; 0.13) | 34
Placebo for 12 weeks after adefovir dipivoxil for 40 weeks, total 52 weeks | HBV DNA <300 copies/mL | 52/52 | 36/120 1/120 | 30/1 | 36.00 (5.02; 258.36) | 0.29 (0.21; 0.38) | 3
Zeng, 2006^40^ Adefovir dipivoxil, 10mg/day, 52 weeks | Placebo for 12 weeks after adefovir dipivoxil for 40 weeks, total 52 weeks | HBV DNA <300 copies/mL | 52/52 | 67/240 1/120 | 28/1 | 33.50 (4.71; 238.38) | 0.27 (0.21; 0.33) | 4
Zeng, 2006^40^ Adefovir dipivoxil, 10mg/day after placebo for 12 weeks, duration of Adefovir dipivoxil 40 weeks, total 52 weeks | Adefovir dipivoxil, 10 mg/day, 52 weeks | HBV DNA <300 copies/mL. | 52/52 | 36/120 67/240 | 30/28 | 1.07 (0.76; 1.51) | 0.02 (-0.08; 0.12) | 48
Zeng, 2006^40^ Adefovir dipivoxil, 10mg/day, 12 weeks | Placebo, 12 weeks | HBeAg loss | 12/12 | 14/240 6/120 | 6/5 | 1.17 (0.46; 2.96) | 0.01 (-0.04; 0.06) | 120
Zeng, 2006^40^ Adefovir dipivoxil, 10mg/day after placebo for 12 weeks, duration of Adefovir dipivoxil 40 weeks, total 52 weeks | Placebo for 12 weeks after Adefovir dipivoxil for 40 weeks, total 52 weeks | HBeAg loss | 52/52 | 24/120 10/120 | 20/8 | 2.40 (1.20; 4.80) | 0.12 (0.03; 0.20) | 9
Zeng, 2006^40^ Adefovir dipivoxil, 10mg/day, 52 weeks | Placebo for 12 weeks after Adefovir dipivoxil for 40 weeks, total 52 weeks | HBeAg loss | 52/52 | 30/240 10/120 | 12/8 | 1.50 (0.76; 2.96) | 0.04 (-0.02; 0.11) | 24
Zeng, 2006^40^ Adefovir dipivoxil, 10mg/day after placebo for 12 weeks, duration of Adefovir dipivoxil 40 weeks, total 52 weeks | Adefovir dipivoxil, 10mg/day, 52 weeks | HBeAg loss | 52/52 | 24/120 30/240 | 20/12 | 1.60 (0.98; 2.61) | 0.08 (-0.01; 0.16) | 13
Zeng, 2006^40^ Adefovir dipivoxil, 10mg/day, 12 weeks | Placebo, 12 weeks | HBeAg seroconversion | 39794 | 14/240 6/120 | 6/5 | 1.17 (0.46; 2.96) | 0.01 (-0.04; 0.06) | 120
Zeng, 2006^40^ Adefovir dipivoxil, 10mg/day after placebo for 12 weeks, duration of Adefovir dipivoxil 40 weeks, total 52 weeks | Placebo for 12 weeks after Adefovir dipivoxil for 40 weeks, total 52 weeks | HBeAg seroconversion | 52/52 | 21/120 8/120 | 18/7 | 2.63 (1.21; 5.69) | 0.11 (0.03; 0.19) | 9
Zeng, 2006^40^ Adefovir dipivoxil, 10mg/day, 52 weeks | Placebo for 12 weeks after Adefovir for 40 weeks, total 52 weeks | HBeAg seroconversion | 52/52 | 19/240 8/120 | 8/7 | 1.19 (0.54; 2.63) | 0.01 (-0.04; 0.07) | 80
Zeng, 2006^40^ Adefovir dipivoxil, 10mg/day after placebo for 12 weeks, duration of Adefovir dipivoxil 40 weeks, total 52 weeks | Adefovir dipivoxil, 10mg/day, 52 weeks | HBeAg seroconversion | 52/52 | 21/120 19/240 | 18/8 | 2.21 (1.24; 3.95) | 0.10 (0.02; 0.17) | 10
Placebo for 12 weeks after Adefovir dipivoxil for 40 weeks, total 52 weeks | Increase in HBV DNA of at least 1 log 10 copies/ml | 52/52 | 11/120 6/120 | 9/5 | 1.83 (0.70; 4.80) | 0.04 (-0.02; 0.11) | 24
Zeng, 2006^40^ Adefovir dipivoxil, 10mg/day, 52 weeks | Placebo for 12 weeks after Adefovir dipivoxil for 40 weeks, total 52 weeks | Increase in HBV DNA of at least 1 log 10 copies/ml | 52/52 | 28/240 6/120 | 12/5 | 2.33 (0.99; 5.48) | 0.07 (0.01; 0.12) | 15
Zeng, 2006^40^ Adefovir dipivoxil, 10mg/day after placebo for 12 weeks, duration of Adefovir dipivoxil 40 weeks, total 52 weeks | Adefovir dipivoxil, 10 mg/day, 52 weeks | Increase in HBV DNA of at least 1 log 10 copies/ml | 52/52 | 11/120 28/240 | 9/12 | 0.79 (0.41; 1.52) | -0.03 (-0.09; 0.04) | -40
Hadziyannis, 2006^97^ Adefovir dipivoxil, 10mg daily, 240 weeks | Adefovir dipivoxil, 10 mg daily, 114 weeks | ALT normalization | 240/114 | 86/125 89/125 | 69/71 | 0.97 (0.82; 1.14) | -0.02 (-0.14; 0.09) | -42
Hadziyannis, 2006^97^ Adefovir dipivoxil, 10mg daily, 240 weeks | Adefovir dipivoxil, 10 mg daily, 114 weeks | Death not related to treatment (car accident) | 240/114 | 0/125 1/125 | 0/1 | 0.33 (0.01; 8.10) | -0.01 (-0.03; 0.01) | -125
Hadziyannis, 2006^97^ Adefovir dipivoxil, 10mg daily, 240 weeks | Adefovir dipivoxil, 10 mg daily, 114 weeks | Treatment failure: hepatocellular carcinoma or harbored HBV with an adefovir resistance mutation and either termination the study or adding lamivudine | 240/114 | 23/125 3/125 | 18/2 | 7.67 (2.36; 24.89) | 0.16 (0.09; 0.23) | 6
Hadziyannis, 2006^97^ Adefovir dipivoxil, 10mg daily, 240 weeks | Adefovir dipivoxil, 10 mg daily, 114 weeks | Hepatocellular carcinoma | 240/114 | 5/125 1/125 | 4/1 | 5.00 (0.59; 42.19) | 0.03 (-0.01; 0.07) | 31
Hadziyannis, 2006^97^ Adefovir dipivoxil, 10mg daily, 240 weeks | Adefovir dipivoxil, 10 mg daily, 114 weeks | Adefovir-resistance mutations with virologic resistance and ALT elevations, virologic resistance, and ALT elevation (clinical resistance) | 240/114 | 14/125 8/125 | 11/6 | 1.75 (0.76; 4.02) | 0.05 (-0.02; 0.12) | 21
Hadziyannis, 2006^97^ Adefovir dipivoxil, 10mg daily, 240 weeks | Adefovir dipivoxil, 10 mg daily, 114 weeks | Any adverse events | 240/114 | 117/125 60/125 | 94/48 | 1.95 (1.62; 2.35) | 0.46 (0.36; 0.55) | 2
Hadziyannis, 2006^97^ Adefovir dipivoxil, 10mg daily, 240 weeks | Adefovir dipivoxil, 10 mg daily, 114 weeks | Abdominal pain | 240/114 | 30/125 20/125 | 24/16 | 1.50 (0.90; 2.49) | 0.08 (-0.02; 0.18) | 12
Hadziyannis, 2006^97^ Adefovir dipivoxil, 10mg daily, 240 weeks | Adefovir dipivoxil, 10 mg daily, 114 weeks | Headache | 240/114 | 29/125 19/125 | 23/15 | 1.53 (0.91; 2.57) | 0.08 (-0.02; 0.18) | 12
Hadziyannis, 2006^97^ Adefovir dipivoxil, 10mg daily, 240 weeks | Adefovir dipivoxil, 10 mg daily, 114 weeks | Flu-like syndrome | 240/114 | 27/125 14/125 | 22/11 | 1.93 (1.06; 3.50) | 0.10 (0.01; 0.19) | 10
Hadziyannis, 2006^97^ Adefovir dipivoxil, 10mg daily, 240 weeks | Adefovir dipivoxil, 10 mg daily, 114 weeks | Asthenia | 240/114 | 20/125 15/125 | 16/12 | 1.33 (0.72; 2.48) | 0.04 (-0.05; 0.13) | 25
Hadziyannis, 2006^97^ Adefovir dipivoxil, 10mg daily, 240 weeks | Adefovir dipivoxil, 10 mg daily, 114 weeks | Infection | 240/114 | 20/125 0/125 | 16/0 | 41.00 (2.51; 670.54) | 0.16 (0.09; 0.23) | 6
Hadziyannis, 2006^97^ Adefovir dipivoxil, 10mg daily, 240 weeks | Adefovir dipivoxil, 10 mg daily, 114 weeks | Back pain | 240/114 | 19/125 9/125 | 15/7 | 2.11 (0.99; 4.48) | 0.08 (0.00; 0.16) | 12
Hadziyannis, 2006^97^ Adefovir dipivoxil, 10mg daily, 240 weeks | Adefovir dipivoxil, 10 mg daily, 114 weeks | Pain | 240/114 | 19/125 12/125 | 15/10 | 1.58 (0.80; 3.12) | 0.06 (-0.03; 0.14) | 18
Hadziyannis, 2006^97^ Adefovir dipivoxil, 10mg daily, 240 weeks | Adefovir dipivoxil, 10 mg daily, 114 weeks | Accidental injury | 240/114 | 15/125 8/125 | 12/6 | 1.88 (0.82; 4.26) | 0.06 (-0.02; 0.13) | 18
Hadziyannis, 2006^97^ Adefovir dipivoxil, 10mg daily, 240 weeks | Adefovir dipivoxil, 10 mg daily, 114 weeks | Dyspepsia | 240/114 | 12/125 7/125 | 10/6 | 1.71 (0.70; 4.21) | 0.04 (-0.03; 0.11) | 25
Hadziyannis, 2006^97^ Adefovir dipivoxil, 10mg daily, 240 weeks | Adefovir dipivoxil, 10 mg daily, 114 weeks | Pharyngitis | 240/114 | 34/125 25/125 | 27/20 | 1.36 (0.86; 2.14) | 0.07 (-0.03; 0.18) | 14
Hadziyannis, 2006^97^ Adefovir dipivoxil, 10mg daily, 240 weeks | Adefovir dipivoxil, 10 mg daily, 114 weeks | Bronchitis | 240/114 | 19/125 9/125 | 15/7 | 2.11 (0.99; 4.48) | 0.08 (0.00; 0.16) | 12
Hadziyannis, 2006^97^ Adefovir dipivoxil, 10mg daily, 240 weeks | Adefovir dipivoxil, 10 mg daily, 114 weeks | Cough increased | 240/114 | 14/125 7/125 | 11/6 | 2.00 (0.84; 4.79) | 0.06 (-0.01; 0.12) | 18
Hadziyannis, 2006^97^ Adefovir dipivoxil, 10mg daily, 240 weeks | Adefovir dipivoxil, 10 mg daily, 114 weeks | Rhinitis | 240/114 | 13/125 0/125 | 10/0 | 27.00 (1.62; 449.30) | 0.10 (0.05; 0.16) | 10
Hadziyannis, 2006^97^ Adefovir dipivoxil, 10mg daily, 240 weeks | Adefovir dipivoxil, 10 mg daily, 114 weeks | At least a 1-point improvement in Ishak fibrosis score | 240/192 | 69/125 89/125 | 55/71 | 0.78 (0.64; 0.94) | -0.16 (-0.28; -0.04) | -6
Hadziyannis, 2006^97^ Adefovir dipivoxil, 10mg daily, 240 weeks | Adefovir dipivoxil, 10 mg daily, 114 weeks | HBV DNA <1000 copies /ml | 240/114 | 84/125 96/125 | 67/77 | 0.88 (0.75; 1.02) | -0.10 (-0.21; 0.01) | -10
Hadziyannis, 2006^97^ Adefovir dipivoxil, 10mg daily, 240 weeks | Adefovir dipivoxil, 10 mg daily, 114 weeks | HBV DNA 1000 to 10,000 copies/mL | 240/114 | 9/125 14/125 | 7/11 | 0.64 (0.29; 1.43) | -0.04 (-0.11; 0.03) | -25
Hadziyannis, 2006^97^ Adefovir dipivoxil, 10mg daily, 240 weeks | Adefovir dipivoxil, 10 mg daily, 114 weeks | HBV DNA 10,000 to 100,000 copies/mL | 240/114 | 6/125 3/125 | 5/2 | 2.02 (0.52; 7.88) | 0.02 (-0.02; 0.07) | 41
Hadziyannis, 2006^97^ Adefovir dipivoxil, 10mg daily, 240 weeks | Adefovir dipivoxil, 10 mg daily, 114 weeks | HBV DNA >100,000 copies/mL | 240/114 | 3/125 10/125 | 2/8 | 0.30 (0.08; 1.06) | -0.06 (-0.11; 0.00) | -18
Hadziyannis, 2006^97^ Adefovir dipivoxil, 10mg daily, 240 weeks | Adefovir dipivoxil, 10 mg daily, 114 weeks | HBsAg loss | 240/114 | 0/125 6/125 | 0/5 | 0.08 (0.00; 1.35) | -0.05 (-0.09; -0.01) | -21
Hadziyannis, 2006^97^ Adefovir dipivoxil, 10mg daily, 240 weeks | Adefovir dipivoxil, 10 mg daily, 114 weeks | HBsAg seroconversion | 240/114 | 0/125 5/125 | 0/4 | 0.09 (0.01; 1.63) | -0.04 (-0.08; 0.00) | -25
Hadziyannis, 2006^97^ Adefovir dipivoxil, 10mg daily, 240 weeks | Adefovir dipivoxil, 10 mg daily, 114 weeks | Adefovir-resistance mutations (N236T or A181V) | 240/114 | 36/125 14/125 | 29/11 | 2.57 (1.46; 4.53) | 0.18 (0.08; 0.27) | 6
Mutation and virologic resistance: adefovir-resistance mutations with HBV DNA increased from nadir by at least 1-log 10 copies/ml or never suppressed to less than 3-log 10 copies /ml | 240/114 | 25/125 10/125 | 20/8 | 2.50 (1.25; 4.99) | 0.12 (0.04; 0.20) | 8
Akyildiz, 2007^45^ Adefovir dipivoxil, 10mg/dayLamivudine, 100mg/day for 3 months 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | ALT flare (>5 times ULN (Grade 3 toxicity)) without any clinical decompensation | 48/48 | 0/29 2/25 | 0/8 | 0.17 (0.01; 3.45) | -0.08 (-0.20; 0.04) | -12
Akyildiz, 2007^45^ Adefovir dipivoxil, 10mg/dayLamivudine, 100mg/day for 3 months 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | Mild ALT elevation according to baseline levels | 48/48 | 8/29 4/25 | 28/16 | 1.72 (0.59; 5.05) | 0.12 (-0.10; 0.33) | 9
Akyildiz, 2007^45^ Adefovir dipivoxil, 10mg/dayLamivudine, 100mg/day for 3 months 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | HBV DNA <2000 copies/ml | 24/24 | 12/29 9/25 | 41/34 | 1.20 (0.60; 2.37) | 0.07 (-0.19; 0.32) | 15
HBV DNA <2000 copies/ml | 48/48 | 17/29 14/25 | 57/56 | 1.05 (0.66; 1.66) | 0.03 (-0.24; 0.29) | 38
Lai, 2002^77^ Entecavir, 0.01mg/day, 24 weeks | Entecavir, 0.1 mg/day, 24 weeks | Normalization of ALT levels when elevated at baseline | 24/24 | 15/52 15/34 | 29/44 | 0.65 (0.37; 1.16) | -0.15 (-0.36; 0.05) | -7
Lai, 2002^77^ Entecavir, 0.01mg/day, 24 weeks | Entecavir, 0.1 mg/day, 24 weeks | ALT >2 × baseline levels | 24/24 | 6/52 6/34 | 12/18 | 0.65 (0.23; 1.86) | -0.06 (-0.22; 0.09) | -16
Lai, 2002^77^ Entecavir, 0.01mg/day, 24 weeks | Entecavir, 0.1 mg/day, 24 weeks | ALT >3 × baseline levels | 24/24 | 2/52 2/34 | 4/6 | 0.65 (0.10; 4.42) | -0.02 (-0.12; 0.07) | -49
Lai, 2002^77^ Entecavir, 0.01mg/day, 24 weeks | ALT >2 × baseline levels and also >10× ULN | 24/24 | 1/52 0/34 | 2/0 | 1.98 (0.08; 47.26) | 0.02 (-0.04; 0.08) | 52
Lai, 2002^77^ Entecavir, 0.01mg/day, 24 weeks | Entecavir, 0.5 mg/day, 24 weeks | Normalization of ALT levels when elevated at baseline | 24/24 | 15/52 20/43 | 29/47 | 0.62 (0.36; 1.06) | -0.18 (-0.37; 0.02) | -6
Lai, 2002^77^ Entecavir, 0.01mg/day, 24 weeks | Entecavir, 0.5 mg/day, 24 weeks | ALT >2 × baseline levels | 24/24 | 6/52 5/43 | 12/12 | 0.99 (0.33; 3.03) | 0.00 (-0.13; 0.13) | -1118
Lai, 2002^77^ Entecavir, 0.01mg/day, 24 weeks | Entecavir, 0.5 mg/day, 24 weeks | ALT >3 × baseline levels | 24/24 | 2/52 1/43 | 4/2 | 1.65 (0.16; 17.63) | 0.02 (-0.05; 0.08) | 66
Lai, 2002^77^ Entecavir, 0.01mg/day, 24 weeks | ALT >2 × baseline levels and also >10× ULN | 24/24 | 1/52 0/43 | 2/0 | 2.49 (0.10; 59.62) | 0.02 (-0.04; 0.07) | 52
Lai, 2002^77^ Entecavir, 0.01mg/day, 24 weeks | Lamivudine, 100 mg/day, 24 weeks | Normalization of ALT levels when elevated at baseline | 24/24 | 15/52 13/40 | 29/32 | 0.89 (0.48; 1.65) | -0.04 (-0.23; 0.15) | -27
Lai, 2002^77^ Entecavir, 0.01mg/day, 24 weeks | Lamivudine, 100 mg/day, 24 weeks | ALT >2 × baseline levels | 24/24 | 6/52 2/40 | 12/5 | 2.31 (0.49; 10.83) | 0.07 (-0.04; 0.18) | 15
Lai, 2002^77^ Entecavir, 0.01mg/day, 24 weeks | Lamivudine, 100 mg/day, 24 weeks | ALT >3 × baseline levels | 24/24 | 2/52 0/40 | 4/0 | 3.87 (0.19; 78.38) | 0.04 (-0.03; 0.10) | 26
ALT >2 × baseline levels and also >10× ULN | 24/24 | 1/52 0/40 | 2/0 | 2.32 (0.10; 55.50) | 0.02 (-0.04; 0.08) | 52
Lai, 2002^77^ Entecavir, 0.1 mg/day, 24 weeks | Entecavir, 0.5 mg/day, 24 weeks | Normalization of ALT levels when elevated at baseline | 24/24 | 15/34 20/43 | 44/47 | 0.95 (0.58; 1.56) | -0.02 (-0.25; 0.20) | -42
Lai, 2002^77^ Entecavir, 0.1 mg/day, 24 weeks | Entecavir, 0.5 mg/day, 24 weeks | ALT >2 × baseline levels | 24/24 | 6/34 5/43 | 18/12 | 1.52 (0.51; 4.55) | 0.06 (-0.10; 0.22) | 17
Lai, 2002^77^ Entecavir, 0.1 mg/day, 24 weeks | Entecavir, 0.5 mg/day, 24 weeks | ALT >3 × baseline levels | 24/24 | 2/34 1/43 | 6/2 | 2.53 (0.24; 26.73) | 0.04 (-0.06; 0.13) | 28
Lai, 2002^77^ Entecavir, 0.1 mg/day, 24 weeks | ALT >2 × baseline levels and also >10× ULN | 24/24 | 0/34 0/43 | | | 0.00 (-0.05; 0.05)
Lai, 2002^77^ Entecavir, 0.1 mg/day, 24 weeks | Lamivudine, 100 mg/day, 24 weeks | Normalization of ALT levels when elevated at baseline | 24/24 | 15/34 13/40 | 44/32 | 1.36 (0.76; 2.44) | 0.12 (-0.11; 0.34) | 9
Lai, 2002^77^ Entecavir, 0.1 mg/day, 24 weeks | Lamivudine, 100 mg/day, 24 weeks | ALT >2 × baseline levels | 24/24 | 6/34 2/40 | 18/5 | 3.53 (0.76; 16.36) | 0.13 (-0.02; 0.27) | 8
Lai, 2002^77^ Entecavir, 0.1 mg/day, 24 weeks | Lamivudine, 100 mg/day, 24 weeks | ALT >3 × baseline levels | 24/24 | 2/34 0/40 | 6/0 | 5.86 (0.29; 117.96) | 0.06 (-0.03; 0.15) | 17
ALT >2 × baseline levels and also >10× ULN | 24/24 | 0/34 0/40 | | | 0.00 (-0.05; 0.05)
Lai, 2002^77^ Entecavir, 0.5 mg/day, 24 weeks | Lamivudine, 100 mg/day, 24 weeks | Normalization of ALT levels when elevated at baseline | 24/24 | 20/43 13/40 | 47/32 | 1.43 (0.83; 2.48) | 0.14 (-0.07; 0.35) | 7
Lai, 2002^77^ Entecavir, 0.5 mg/day, 24 weeks | Lamivudine, 100 mg/day, 24 weeks
Lai, 2002^77^ Entecavir, 0.5 mg/day, 24 weeks | Lamivudine, 100 mg/day, 24 weeks | ALT >2 × baseline levels | 24/24 | 5/43 2/40 | 12/5 | 2.33 (0.48; 11.32) | 0.07 (-0.05; 0.18) | 15
ALT >3 × baseline levels | 24/24 | 1/43 0/40 | 2/0 | 2.80 (0.12; 66.70) | 0.02 (-0.04; 0.09) | 43
ALT >2 × baseline levels and also >10× ULN | 24/24 | 0/43 0/40 | | | 0.00 (-0.05; 0.05)
Lai, 2002^77^ Entecavir, 0.01 mg/day, 24 weeks | Entecavir, 0.1 mg/day, 24 weeks | HBV-DNA loss by branched-chain assay + HBeAg loss + normal ALT for HBeAg+ at baseline and HBV-DNA loss + normal ALT for HBeAg- at baseline | 24/24 | 12/52 21/34 | 23/62 | 0.37 (0.21; 0.66) | -0.39 (-0.59; -0.19) | -3
Lai, 2002^77^ Entecavir, 0.01 mg/day, 24 weeks
Lai, 2002^77^ Entecavir, 0.01 mg/day, 24 weeks | Entecavir, 0.1 mg/day, 24 weeks | HBV-DNA loss by branched-chain assay + HBeAg loss + normal ALT for HBeAg+ at baseline and HBV-DNA loss by branched-chain assay + normal ALT for HBeAg- at baseline | 24/24 | 3/52 8/34 | 6/24 | 0.25 (0.07; 0.86) | -0.18 (-0.33; -0.02) | -6
Lai, 2002^77^ Entecavir, 0.01 mg/day, 24 weeks
Lai, 2002^77^ Entecavir, 0.01 mg/day, 24 weeks | Entecavir, 0.1 mg/day, 24 weeks | HBV-DNA loss by branched-chain assay + present HBeAg or elevated ALT for HBeAg+ at baseline or HBV-DNA loss+ elevated ALT for HBeAg- at baseline | 24/24 | 9/52 13/34 | 17/38 | 0.45 (0.22; 0.94) | -0.21 (-0.40; -0.02) | -5
Lai, 2002^77^ Entecavir, 0.01 mg/day, 24 weeks
Lai, 2002^77^ Entecavir, 0.01 mg/day, 24 weeks | Entecavir, 0.5 mg/day, 24 weeks | Complete or partial response (see above) | 24/24 | 12/52 36/43 | 23/84 | 0.28 (0.16; 0.46) | -0.61 (-0.77; -0.45) | -2
Lai, 2002^77^ Entecavir, 0.01 mg/day, 24 weeks
Entecavir, 0.5 mg/day, 24 weeks | Complete response | 24/24 | 3/52 7/43 | 6/16 | 0.35 (0.10; 1.29) | -0.11 (-0.23; 0.02) | -10
Entecavir, 0.5 mg/day, 24 weeks | Partial response | 24/24 | 9/52 29/43 | 17/67 | 0.26 (0.14; 0.48) | -0.50 (-0.68; -0.33) | -2
Lamivudine, 100 mg/day, 24 weeks | Complete or partial response (see above) | 24/24 | 12/52 23/40 | 23/57 | 0.40 (0.23; 0.70) | -0.34 (-0.54; -0.15) | -3
Lamivudine, 100 mg/day, 24 weeks | Complete response | 24/24 | 3/52 6/40 | 6/15 | 0.38 (0.10; 1.44) | -0.09 (-0.22; 0.04) | -11
Lamivudine, 100 mg/day, 24 weeks | Partial response | 24/24 | 9/52 17/40 | 17/42 | 0.41 (0.20; 0.82) | -0.25 (-0.44; -0.07) | -4
Lai, 2002^77^ Entecavir, 0.1mg/day, 24 weeks | Entecavir, 0.5 mg/day, 24 weeks | Complete or partial response (see above) | 24/24 | 21/34 36/43 | 62/84 | 0.74 (0.55; 0.99) | -0.22 (-0.42; -0.02) | -5
Lai, 2002^77^ Entecavir, 0.1mg/day, 24 weeks
Lai, 2002^77^ Entecavir, 0.1mg/day, 24 weeks | Entecavir, 0.5 mg/day, 24 weeks | Complete response | 24/24 | 8/34 7/43 | 24/16 | 1.45 (0.58; 3.59) | 0.07 (-0.11; 0.25) | 14
Lai, 2002^77^ Entecavir, 0.1mg/day, 24 weeks
Lai, 2002^77^ Entecavir, 0.1mg/day, 24 weeks | Entecavir, 0.5 mg/day, 24 weeks | Partial response | 24/24 | 13/34 29/43 | 38/67 | 0.57 (0.35; 0.91) | -0.29 (-0.51; -0.08) | -3
Lamivudine, 100 mg/day, 24 weeks | Complete or partial response (see above) | 24/24 | 21/34 23/40 | 62/57 | 1.07 (0.74; 1.56) | 0.04 (-0.18; 0.27) | 23
Lamivudine, 100 mg/day, 24 weeks | Complete response | 24/24 | 8/34 6/40 | 24/15 | 1.57 (0.60; 4.08) | 0.09 (-0.10; 0.27) | 12
Lamivudine, 100 mg/day, 24 weeks | Partial response | 24/24 | 13/34 17/40 | 38/42 | 0.90 (0.51; 1.57) | -0.04 (-0.27; 0.18) | -23
Lai, 2002^77^ Entecavir, 0.5mg/day, 24 weeks | Lamivudine, 100 mg/day, 24 weeks | Complete or partial response (see above) | 24/24 | 36/43 23/40 | 84/57 | 1.46 (1.08; 1.96) | 0.26 (0.07; 0.45) | 4
Lai, 2002^77^ Entecavir, 0.5mg/day, 24 weeks
Lamivudine, 100 mg/day, 24 weeks | Complete response | 24/24 | 7/43 6/40 | 16/15 | 1.09 (0.40; 2.96) | 0.01 (-0.14; 0.17) | 78
Lamivudine, 100 mg/day, 24 weeks | Partial response | 24/24 | 29/43 17/40 | 67/42 | 1.59 (1.05; 2.41) | 0.25 (0.04; 0.46) | 4
Lai, 2002^77^ Entecavir, 0.01mg/day, 24 weeks | Entecavir, 0.1 mg/day, 24 weeks | Bilirubin >2× baseline levels | 24/24 | 4/52 2/34 | 8/6 | 1.31 (0.25; 6.75) | 0.02 (-0.09; 0.13) | 55
Lai, 2002^77^ Entecavir, 0.01mg/day, 24 weeks | Entecavir, 0.1 mg/day, 24 weeks
Lai, 2002^77^ Entecavir, 0.01mg/day, 24 weeks | Entecavir, 0.1 mg/day, 24 weeks | Bilirubin >3× baseline levels | 24/24 | 1/52 0/34 | 2/0 | 1.98 (0.08; 47.26) | 0.02 (-0.04; 0.08) | 52
Lai, 2002^77^ Entecavir, 0.01mg/day, 24 weeks
Lai, 2002^77^ Entecavir, 0.01mg/day, 24 weeks | Bilirubin >2× baseline levels and also 5× ULN | 24/24 | 1/52 0/34 | 2/0 | 1.98 (0.08; 47.26) | 0.02 (-0.04; 0.08) | 52
Lai, 2002^77^ Entecavir, 0.01mg/day, 24 weeks
Lai, 2002^77^ Entecavir, 0.01mg/day, 24 weeks | ALT ≥2 baseline levels and bilirubin ≥2 baseline levels with bilirubin 2× ULN | 24/24 | 0/52 0/34 | | | 0.00 (-0.05; 0.05)
Lai, 2002^77^ Entecavir, 0.01mg/day, 24 weeks
Lai, 2002^77^ Entecavir, 0.01mg/day, 24 weeks | Entecavir, 0.5 mg/day, 24 weeks | Bilirubin >2× baseline levels | 24/24 | 4/52 4/43 | 8/9 | 0.83 (0.22; 3.11) | -0.02 (-0.13; 0.10) | -62
Lai, 2002^77^ Entecavir, 0.01mg/day, 24 weeks | Entecavir, 0.5 mg/day, 24 weeks
Lai, 2002^77^ Entecavir, 0.01mg/day, 24 weeks | Entecavir, 0.5 mg/day, 24 weeks | Bilirubin >3× baseline levels | 24/24 | 1/52 1/43 | 2/2 | 0.83 (0.05; 12.83) | 0.00 (-0.06; 0.05) | -248
Bilirubin >2× baseline levels and also 5× ULN | 24/24 | 1/52 0/43 | 2/0 | 2.49 (0.10; 59.62) | 0.02 (-0.04; 0.07) | 52
ALT ≥2 baseline levels and bilirubin ≥2 baseline levels with bilirubin 2 × ULN | 24/24 | 0/52 0/43 | | | 0.00 (-0.04; 0.04)
Lamivudine, 100 mg/day, 24 weeks | Bilirubin >2× baseline levels | 24/24 | 4/52 2/40 | 8/5 | 1.54 (0.30; 7.98) | 0.03 (-0.07; 0.13) | 37
Lamivudine, 100 mg/day, 24 weeks
Lamivudine, 100 mg/day, 24 weeks | Bilirubin >3× baseline levels | 24/24 | 1/52 1/40 | 2/2 | 0.77 (0.05; 11.92) | -0.01 (-0.07; 0.06) | -173
Bilirubin >2× baseline levels and also 5× ULN | 24/24 | 1/52 0/40 | 2/0 | 2.32 (0.10; 55.50) | 0.02 (-0.04; 0.08) | 52
ALT ≥2 baseline levels and bilirubin ≥2 baseline levels with bilirubin 2 × ULN | 24/24 | 0/52 0/40 | | | 0.00 (-0.04; 0.04)
Lai, 2002^77^ Entecavir, 0.1 mg/day, 24 weeks | Entecavir, 0.5 mg/day, 24 weeks | Bilirubin >2× baseline levels | 24/24 | 2/34 4/43 | 6/9 | 0.63 (0.12; 3.25) | -0.03 (-0.15; 0.08) | -29
Lai, 2002^77^ Entecavir, 0.1 mg/day, 24 weeks | Entecavir, 0.5 mg/day, 24 weeks
Lai, 2002^77^ Entecavir, 0.1 mg/day, 24 weeks | Entecavir, 0.5 mg/day, 24 weeks | Bilirubin >3× baseline levels | 24/24 | 0/34 1/43 | 0/2 | 0.42 (0.02; 9.97) | -0.02 (-0.09; 0.04) | -43
Lai, 2002^77^ Entecavir, 0.1 mg/day, 24 weeks
Lai, 2002^77^ Entecavir, 0.1 mg/day, 24 weeks | Bilirubin >2× baseline levels and also 5× ULN | 24/24 | 0/34 0/43 | | | 0.00 (-0.05; 0.05)
Lai, 2002^77^ Entecavir, 0.1 mg/day, 24 weeks
Lai, 2002^77^ Entecavir, 0.1 mg/day, 24 weeks | ALT >2 baseline levels and bilirubin >2 baseline levels with bilirubin 2 × ULN | 24/24 | 0/34 0/43 | | | 0.00 (-0.05; 0.05)
Lamivudine, 100 mg/day, 24 weeks | Bilirubin >2× baseline levels | 24/24 | 2/34 2/40 | 6/5 | 1.18 (0.17; 7.91) | 0.01 (-0.10; 0.11) | 113
Lamivudine, 100 mg/day, 24 weeks
Lamivudine, 100 mg/day, 24 weeks | Bilirubin >3× baseline levels | 24/24 | 0/34 1/40 | 0/2 | 0.39 (0.02; 9.28) | -0.03 (-0.09; 0.04) | -40
Bilirubin >2× baseline levels and also 5× ULN | 24/24 | 0/34 0/40 | | | 0.00 (-0.05; 0.05)
ALT >2 baseline levels and bilirubin >2 baseline levels with bilirubin 2 × ULN | 24/24 | 0/34 0/40 | | | 0.00 (-0.05; 0.05)
Lai, 2002^77^ Entecavir, 0.5 mg/day, 24 weeks | Lamivudine, 100 mg/day, 24 weeks | Bilirubin >2× baseline levels | 24/24 | 4/43 2/40 | 9/5 | 1.86 (0.36; 9.61) | 0.04 (-0.07; 0.15) | 23
Lai, 2002^77^ Entecavir, 0.5 mg/day, 24 weeks | Lamivudine, 100 mg/day, 24 weeks
Lai, 2002^77^ Entecavir, 0.5 mg/day, 24 weeks | Lamivudine, 100 mg/day, 24 weeks | Bilirubin >3× baseline levels | 24/24 | 1/43 1/40 | 2/2 | 0.93 (0.06; 14.38) | 0.00 (-0.07; 0.06) | -573
Bilirubin >2× baseline levels and also 5× ULN | 24/24 | 0/43 0/40 | | | 0.00 (-0.05; 0.05)
ALT >2 baseline levels and bilirubin >2 baseline levels with bilirubin 2 × ULN | 24/24 | 0/43 0/40 | | | 0.00 (-0.05; 0.05)
Lai, 2002^77^ Entecavir, 0.01 mg/day, 24 weeks | Entecavir, 0.1 mg/day, 24 weeks | Any adverse event | 24/24 | 38/52 25/34 | 73/74 | 0.99 (0.77; 1.29) | 0.00 (-0.20; 0.19) | -221
Lai, 2002^77^ Entecavir, 0.01 mg/day, 24 weeks | Entecavir, 0.1 mg/day, 24 weeks
Lai, 2002^77^ Entecavir, 0.01 mg/day, 24 weeks | Entecavir, 0.1 mg/day, 24 weeks | Headache | 24/24 | 11/52 12/34 | 21/35 | 0.60 (0.30; 1.20) | -0.14 (-0.34; 0.05) | -7
Lai, 2002^77^ Entecavir, 0.01 mg/day, 24 weeks | Entecavir, 0.1 mg/day, 24 weeks
Lai, 2002^77^ Entecavir, 0.01 mg/day, 24 weeks | Entecavir, 0.1 mg/day, 24 weeks | Abdominal pain | 24/24 | 12/52 11/34 | 23/32 | 0.71 (0.36; 1.43) | -0.09 (-0.29; 0.10) | -11
Lai, 2002^77^ Entecavir, 0.01 mg/day, 24 weeks | Entecavir, 0.1 mg/day, 24 weeks
Lai, 2002^77^ Entecavir, 0.01 mg/day, 24 weeks | Entecavir, 0.1 mg/day, 24 weeks | Rhinitis | 24/24 | 9/52 8/34 | 17/24 | 0.74 (0.31; 1.72) | -0.06 (-0.24; 0.11) | -16
Lai, 2002^77^ Entecavir, 0.01 mg/day, 24 weeks | Entecavir, 0.1 mg/day, 24 weeks
Lai, 2002^77^ Entecavir, 0.01 mg/day, 24 weeks | Entecavir, 0.1 mg/day, 24 weeks | Fatigue | 24/24 | 6/52 6/34 | 12/18 | 0.65 (0.23; 1.86) | -0.06 (-0.22; 0.09) | -16
Lai, 2002^77^ Entecavir, 0.01 mg/day, 24 weeks | Entecavir, 0.1 mg/day, 24 weeks
Lai, 2002^77^ Entecavir, 0.01 mg/day, 24 weeks | Fever | 24/24 | 5/52 5/34 | 10/15 | 0.65 (0.20; 2.09) | -0.05 (-0.19; 0.09) | -20
Lai, 2002^77^ Entecavir, 0.01 mg/day, 24 weeks
Lai, 2002^77^ Entecavir, 0.01 mg/day, 24 weeks | Diarrhea | 24/24 | 3/52 4/34 | 6/12 | 0.49 (0.12; 2.06) | -0.06 (-0.19; 0.07) | -17
Lai, 2002^77^ Entecavir, 0.01 mg/day, 24 weeks
Lai, 2002^77^ Entecavir, 0.01 mg/day, 24 weeks | Nausea | 24/24 | 3/52 2/34 | 6/6 | 0.98 (0.17; 5.57) | 0.00 (-0.10; 0.10) | -884
Lai, 2002^77^ Entecavir, 0.01 mg/day, 24 weeks
Lai, 2002^77^ Entecavir, 0.01 mg/day, 24 weeks | Dizziness | 24/24 | 3/52 1/34 | 6/3 | 1.96 (0.21; 18.09) | 0.03 (-0.06; 0.11) | 35
Lai, 2002^77^ Entecavir, 0.01 mg/day, 24 weeks
Lai, 2002^77^ Entecavir, 0.01 mg/day, 24 weeks | Cough | 24/24 | 2/52 5/34 | 4/15 | 0.26 (0.05; 1.27) | -0.11 (-0.24; 0.02) | -9
Lai, 2002^77^ Entecavir, 0.01 mg/day, 24 weeks
Lai, 2002^77^ Entecavir, 0.01 mg/day, 24 weeks | Myalgia | 24/24 | 2/52 2/34 | 4/6 | 0.65 (0.10; 4.42) | -0.02 (-0.12; 0.07) | -49
Lai, 2002^77^ Entecavir, 0.01 mg/day, 24 weeks
Lai, 2002^77^ Entecavir, 0.01 mg/day, 24 weeks | Entecavir, 0.5 mg/day, 24 weeks | Any adverse event | 24/24 | 38/52 30/43 | 73/70 | 1.05 (0.81; 1.35) | 0.03 (-0.15; 0.22) | 30
Lai, 2002^77^ Entecavir, 0.01 mg/day, 24 weeks | Entecavir, 0.5 mg/day, 24 weeks
Lai, 2002^77^ Entecavir, 0.01 mg/day, 24 weeks | Entecavir, 0.5 mg/day, 24 weeks | Headache | 24/24 | 11/52 14/43 | 21/33 | 0.65 (0.33; 1.28) | -0.11 (-0.29; 0.06) | -9
Lai, 2002^77^ Entecavir, 0.01 mg/day, 24 weeks | Entecavir, 0.5 mg/day, 24 weeks
Lai, 2002^77^ Entecavir, 0.01 mg/day, 24 weeks | Entecavir, 0.5 mg/day, 24 weeks | Abdominal pain | 24/24 | 12/52 12/43 | 23/28 | 0.83 (0.41; 1.65) | -0.05 (-0.22; 0.13) | -21
Lai, 2002^77^ Entecavir, 0.01 mg/day, 24 weeks | Entecavir, 0.5 mg/day, 24 weeks
Lai, 2002^77^ Entecavir, 0.01 mg/day, 24 weeks | Entecavir, 0.5 mg/day, 24 weeks | Rhinitis | 24/24 | 9/52 5/43 | 17/12 | 1.49 (0.54; 4.11) | 0.06 (-0.08; 0.20) | 18
Lai, 2002^77^ Entecavir, 0.01 mg/day, 24 weeks | Entecavir, 0.5 mg/day, 24 weeks
Lai, 2002^77^ Entecavir, 0.01 mg/day, 24 weeks | Entecavir, 0.5 mg/day, 24 weeks | Fatigue | 24/24 | 6/52 8/43 | 12/19 | 0.62 (0.23; 1.65) | -0.07 (-0.22; 0.07) | -14
Lai, 2002^77^ Entecavir, 0.01 mg/day, 24 weeks | Entecavir, 0.5 mg/day, 24 weeks
Fever | 24/24 | 5/52 2/43 | 10/5 | 2.07 (0.42; 10.13) | 0.05 (-0.05; 0.15) | 20
Diarrhea | 24/24 | 3/52 5/43 | 6/12 | 0.50 (0.13; 1.96) | -0.06 (-0.17; 0.06) | -17
Nausea | 24/24 | 3/52 5/43 | 6/12 | 0.50 (0.13; 1.96) | -0.06 (-0.17; 0.06) | -17
Dizziness | 24/24 | 3/52 5/43 | 6/12 | 0.50 (0.13; 1.96) | -0.06 (-0.17; 0.06) | -17
Cough | 24/24 | 2/52 2/43 | 4/5 | 0.83 (0.12; 5.63) | -0.01 (-0.09; 0.07) | -124
Myalgia | 24/24 | 2/52 0/43 | 4/0 | 4.15 (0.20; 84.21) | 0.04 (-0.03; 0.10) | 26
Lamivudine, 100 mg/day, 24 weeks | Any adverse event | 24/24 | 38/52 30/40 | 73/75 | 0.97 (0.76; 1.24) | -0.02 (-0.20; 0.16) | -52
Lamivudine, 100 mg/day, 24 weeks
Lamivudine, 100 mg/day, 24 weeks | Headache | 24/24 | 11/52 8/40 | 21/20 | 1.06 (0.47; 2.38) | 0.01 (-0.15; 0.18) | 87
Lamivudine, 100 mg/day, 24 weeks
Lamivudine, 100 mg/day, 24 weeks | Abdominal pain | 24/24 | 12/52 7/40 | 23/18 | 1.32 (0.57; 3.04) | 0.06 (-0.11; 0.22) | 18
Lamivudine, 100 mg/day, 24 weeks
Lamivudine, 100 mg/day, 24 weeks | Rhinitis | 24/24 | 9/52 8/40 | 17/20 | 0.87 (0.37; 2.04) | -0.03 (-0.19; 0.13) | -37
Lamivudine, 100 mg/day, 24 weeks
Lamivudine, 100 mg/day, 24 weeks | Fatigue | 24/24 | 6/52 7/40 | 12/18 | 0.66 (0.24; 1.81) | -0.06 (-0.21; 0.09) | -17
Lamivudine, 100 mg/day, 24 weeks
Fever | 24/24 | 5/52 6/40 | 10/15 | 0.64 (0.21; 1.95) | -0.05 (-0.19; 0.08) | -19
Diarrhea | 24/24 | 3/52 4/40 | 6/10 | 0.58 (0.14; 2.43) | -0.04 (-0.15; 0.07) | -24
Nausea | 24/24 | 3/52 3/40 | 6/8 | 0.77 (0.16; 3.61) | -0.02 (-0.12; 0.09) | -58
Dizziness | 24/24 | 3/52 2/40 | 6/5 | 1.15 (0.20; 6.58) | 0.01 (-0.08; 0.10) | 130
Cough | 24/24 | 2/52 2/40 | 4/5 | 0.77 (0.11; 5.23) | -0.01 (-0.10; 0.07) | -87
Myalgia | 24/24 | 2/52 4/40 | 4/10 | 0.38 (0.07; 2.00) | -0.06 (-0.17; 0.05) | -16
Lai, 2002^77^ Entecavir, 0.1 mg/day, 24 weeks | Entecavir, 0.5 mg/day, 24 weeks | Any adverse event | 24/24 | 25/34 30/43 | 74/70 | 1.05 (0.80; 1.40) | 0.04 (-0.16; 0.24) | 27
Lai, 2002^77^ Entecavir, 0.1 mg/day, 24 weeks | Entecavir, 0.5 mg/day, 24 weeks
Lai, 2002^77^ Entecavir, 0.1 mg/day, 24 weeks | Entecavir, 0.5 mg/day, 24 weeks | Headache | 24/24 | 12/34 14/43 | 35/33 | 1.08 (0.58; 2.03) | 0.03 (-0.19; 0.24) | 37
Lai, 2002^77^ Entecavir, 0.1 mg/day, 24 weeks | Entecavir, 0.5 mg/day, 24 weeks
Lai, 2002^77^ Entecavir, 0.1 mg/day, 24 weeks | Entecavir, 0.5 mg/day, 24 weeks | Abdominal pain | 24/24 | 11/34 12/43 | 32/28 | 1.16 (0.59; 2.30) | 0.04 (-0.16; 0.25) | 22
Lai, 2002^77^ Entecavir, 0.1 mg/day, 24 weeks | Entecavir, 0.5 mg/day, 24 weeks
Lai, 2002^77^ Entecavir, 0.1 mg/day, 24 weeks | Entecavir, 0.5 mg/day, 24 weeks | Rhinitis | 24/24 | 8/34 5/43 | 24/12 | 2.02 (0.73; 5.63) | 0.12 (-0.05; 0.29) | 8
Lai, 2002^77^ Entecavir, 0.1 mg/day, 24 weeks | Entecavir, 0.5 mg/day, 24 weeks
Lai, 2002^77^ Entecavir, 0.1 mg/day, 24 weeks | Entecavir, 0.5 mg/day, 24 weeks | Fatigue | 24/24 | 6/34 8/43 | 18/19 | 0.95 (0.36; 2.47) | -0.01 (-0.18; 0.16) | -104
Lai, 2002^77^ Entecavir, 0.1 mg/day, 24 weeks | Entecavir, 0.5 mg/day, 24 weeks
Lai, 2002^77^ Entecavir, 0.1 mg/day, 24 weeks | Fever | 24/24 | 5/34 2/43 | 15/5 | 3.16 (0.65; 15.30) | 0.10 (-0.03; 0.24) | 10
Lai, 2002^77^ Entecavir, 0.1 mg/day, 24 weeks
Lai, 2002^77^ Entecavir, 0.1 mg/day, 24 weeks | Diarrhea | 24/24 | 4/34 5/43 | 12/12 | 1.01 (0.29; 3.48) | 0.00 (-0.14; 0.15) | 731
Lai, 2002^77^ Entecavir, 0.1 mg/day, 24 weeks
Lai, 2002^77^ Entecavir, 0.1 mg/day, 24 weeks | Nausea | 24/24 | 2/34 5/43 | 6/12 | 0.51 (0.10; 2.45) | -0.06 (-0.18; 0.07) | -17
Lai, 2002^77^ Entecavir, 0.1 mg/day, 24 weeks
Lai, 2002^77^ Entecavir, 0.1 mg/day, 24 weeks | Dizziness | 24/24 | 1/34 5/43 | 3/12 | 0.25 (0.03; 2.06) | -0.09 (-0.20; 0.02) | -12
Lai, 2002^77^ Entecavir, 0.1 mg/day, 24 weeks
Lai, 2002^77^ Entecavir, 0.1 mg/day, 24 weeks | Cough | 24/24 | 5/34 2/43 | 15/5 | 3.16 (0.65; 15.30) | 0.10 (-0.03; 0.24) | 10
Lai, 2002^77^ Entecavir, 0.1 mg/day, 24 weeks
Lai, 2002^77^ Entecavir, 0.1 mg/day, 24 weeks | Myalgia | 24/24 | 2/34 0/43 | 6/0 | 6.29 (0.31; 126.72) | 0.06 (-0.03; 0.15) | 17
Lamivudine, 100 mg/day, 24 weeks | Any adverse event | 24/24 | 25/34 30/40 | 74/75 | 0.98 (0.75; 1.28) | -0.01 (-0.21; 0.19) | -68
Lamivudine, 100 mg/day, 24 weeks
Lamivudine, 100 mg/day, 24 weeks | Headache | 24/24 | 12/34 8/40 | 35/20 | 1.76 (0.82; 3.81) | 0.15 (-0.05; 0.36) | 7
Lamivudine, 100 mg/day, 24 weeks
Lamivudine, 100 mg/day, 24 weeks | Abdominal pain | 24/24 | 11/34 7/40 | 32/18 | 1.85 (0.81; 4.24) | 0.15 (-0.05; 0.34) | 7
Lamivudine, 100 mg/day, 24 weeks
Lamivudine, 100 mg/day, 24 weeks | Rhinitis | 24/24 | 8/34 8/40 | 24/20 | 1.18 (0.49; 2.80) | 0.04 (-0.15; 0.22) | 28
Lamivudine, 100 mg/day, 24 weeks
Lamivudine, 100 mg/day, 24 weeks | Fatigue | 24/24 | 6/34 7/40 | 18/18 | 1.01 (0.37; 2.71) | 0.00 (-0.17; 0.18) | 680
Lamivudine, 100 mg/day, 24 weeks
Fever | 24/24 | 5/34 6/40 | 15/15 | 0.98 (0.33; 2.93) | 0.00 (-0.17; 0.16) | -340
Diarrhea | 24/24 | 4/34 4/40 | 12/10 | 1.18 (0.32; 4.35) | 0.02 (-0.13; 0.16) | 57
Nausea | 24/24 | 2/34 3/40 | 6/8 | 0.78 (0.14; 4.42) | -0.02 (-0.13; 0.10) | -62
Dizziness | 24/24 | 1/34 2/40 | 3/5 | 0.59 (0.06; 6.21) | -0.02 (-0.11; 0.07) | -49
Cough | 24/24 | 5/34 2/40 | 15/5 | 2.94 (0.61; 14.21) | 0.10 (-0.04; 0.23) | 10
Myalgia | 24/24 | 2/34 4/40 | 6/10 | 0.59 (0.11; 3.02) | -0.04 (-0.16; 0.08) | -24
Lai, 2002^77^ Entecavir, 0.5 mg/day, 24 weeks | Lamivudine, 100 mg/day, 24 weeks | Any adverse event | 24/24 | 30/43 30/40 | 70/75 | 0.93 (0.71; 1.21) | -0.05 (-0.24; 0.14) | -19
Lai, 2002^77^ Entecavir, 0.5 mg/day, 24 weeks | Lamivudine, 100 mg/day, 24 weeks
Lai, 2002^77^ Entecavir, 0.5 mg/day, 24 weeks | Lamivudine, 100 mg/day, 24 weeks | Headache | 24/24 | 14/43 8/40 | 33/20 | 1.63 (0.77; 3.46) | 0.13 (-0.06; 0.31) | 8
Lai, 2002^77^ Entecavir, 0.5 mg/day, 24 weeks | Lamivudine, 100 mg/day, 24 weeks
Lai, 2002^77^ Entecavir, 0.5 mg/day, 24 weeks | Lamivudine, 100 mg/day, 24 weeks | Abdominal pain | 24/24 | 12/43 7/40 | 28/18 | 1.59 (0.70; 3.65) | 0.10 (-0.07; 0.28) | 10
Lai, 2002^77^ Entecavir, 0.5 mg/day, 24 weeks | Lamivudine, 100 mg/day, 24 weeks
Lai, 2002^77^ Entecavir, 0.5 mg/day, 24 weeks | Lamivudine, 100 mg/day, 24 weeks | Rhinitis | 24/24 | 5/43 8/40 | 12/20 | 0.58 (0.21; 1.63) | -0.08 (-0.24; 0.07) | -12
Lai, 2002^77^ Entecavir, 0.5 mg/day, 24 weeks | Lamivudine, 100 mg/day, 24 weeks
Lai, 2002^77^ Entecavir, 0.5 mg/day, 24 weeks | Lamivudine, 100 mg/day, 24 weeks | Fatigue | 24/24 | 8/43 7/40 | 19/18 | 1.06 (0.42; 2.66) | 0.01 (-0.15; 0.18) | 91
Lai, 2002^77^ Entecavir, 0.5 mg/day, 24 weeks | Lamivudine, 100 mg/day, 24 weeks
Fever | 24/24 | 2/43 6/40 | 5/15 | 0.31 (0.07; 1.45) | -0.10 (-0.23; 0.02) | -10
Diarrhea | 24/24 | 5/43 4/40 | 12/10 | 1.16 (0.34; 4.03) | 0.02 (-0.12; 0.15) | 61
Nausea | 24/24 | 5/43 3/40 | 12/8 | 1.55 (0.40; 6.07) | 0.04 (-0.08; 0.17) | 24
Dizziness | 24/24 | 5/43 2/40 | 12/5 | 2.33 (0.48; 11.32) | 0.07 (-0.05; 0.18) | 15
Cough | 24/24 | 2/43 2/40 | 5/5 | 0.93 (0.14; 6.30) | 0.00 (-0.10; 0.09) | -287
Myalgia | 24/24 | 0/43 4/40 | 0/10 | 0.10 (0.01; 1.86) | -0.10 (-0.20; 0.00) | -10
Lai, 2002^77^ Entecavir, 0.01 mg/day, 24 weeks | Entecavir, 0.1 mg/day, 24 weeks | Undetectable HBV DNA using Amplicor PCR assay | 24/24 | 1/52 9/34 | 2/26 | 0.07 (0.01; 0.55) | -0.25 (-0.40; -0.09) | -4
Lai, 2002^77^ Entecavir, 0.01 mg/day, 24 weeks
Entecavir, 0.5 mg/day, 24 weeks | Undetectable HBV DNA using Amplicor PCR assay | 24/24 | 1/52 11/43 | 2/26 | 0.08 (0.01; 0.56) | -0.24 (-0.37; -0.10) | -4
Lamivudine, 100 mg/day, 24 weeks | Undetectable HBV DNA using Amplicor PCR assay | 24/24 | 1/52 7/40 | 2/18 | 0.11 (0.01; 0.86) | -0.16 (-0.28; -0.03) | -6
Lai, 2002^77^ Entecavir, 0.1 mg/day, 24 weeks | Entecavir, 0.5 mg/day, 24 weeks | Undetectable HBV DNA using Amplicor PCR assay | 24/24 | 9/34 11/43 | 26/26 | 1.03 (0.49; 2.21) | 0.01 (-0.19; 0.21) | 112
Lamivudine, 100 mg/day, 24 weeks | Undetectable HBV DNA using Amplicor PCR assay | 24/24 | 9/34 7/40 | 26/18 | 1.51 (0.63; 3.63) | 0.09 (-0.10; 0.28) | 11
Lai, 2002^77^ Entecavir, 0.5 mg/day, 24 weeks | Lamivudine, 100 mg/day, 24 weeks | Undetectable HBV DNA using Amplicor PCR assay | 24/24 | 11/43 7/40 | 26/18 | 1.46 (0.63; 3.40) | 0.08 (-0.09; 0.26) | 12
Lai, 2002^77^ Entecavir, 0.01 mg/day, 24 weeks | Entecavir, 0.1 mg/day, 24 weeks | Undetectable HBV DNA using Quantiplex bDNA assay | 24/24 | 12/52 21/34 | 23/62 | 0.37 (0.21; 0.66) | -0.39 (-0.59; -0.19) | -3
Lai, 2002^77^ Entecavir, 0.01 mg/day, 24 weeks
Entecavir, 0.5 mg/day, 24 weeks | Undetectable HBV DNA using Quantiplex bDNA assay | 24/24 | 12/52 36/43 | 23/84 | 0.28 (0.16; 0.46) | -0.61 (-0.77; -0.45) | -2
Lamivudine, 100 mg/day, 24 weeks | Undetectable HBV DNA using Quantiplex bDNA assay | 24/24 | 12/52 23/40 | 23/57 | 0.40 (0.23; 0.70) | -0.34 (-0.54; -0.15) | -3
Lai, 2002^77^ Entecavir, 0.1 mg/day, 24 weeks | Entecavir, 0.5 mg/day, 24 weeks | Undetectable HBV DNA using Quantiplex bDNA assay | 24/24 | 21/34 36/43 | 62/84 | 0.74 (0.55; 0.99) | -0.22 (-0.42; -0.02) | -5
Lamivudine, 100 mg/day, 24 weeks | Undetectable HBV DNA using Quantiplex bDNA assay | 24/24 | 21/34 23/40 | 62/57 | 1.07 (0.74; 1.56) | 0.04 (-0.18; 0.27) | 23
Lai, 2002^77^ Entecavir, 0.5 mg/day, 24 weeks | Lamivudine, 100 mg/day, 24 weeks | Undetectable HBV DNA using Quantiplex bDNA assay | 24/24 | 36/43 23/40 | 84/57 | 1.46 (1.08; 1.96) | 0.26 (0.07; 0.45) | 4
Lai, 2002^77^ Entecavir, 0.01 mg/day, 24 weeks | Entecavir, 0.1 mg/day, 24 weeks | HBV-DNA levels still detectable by branched-chain assay | 24/24 | 40/52 13/34 | 77/38 | 2.01 (1.28; 3.16) | 0.39 (0.19; 0.59) | 3
Lai, 2002^77^ Entecavir, 0.01 mg/day, 24 weeks
Entecavir, 0.5 mg/day, 24 weeks | HBV-DNA levels still detectable by branched-chain assay | 24/24 | 40/52 7/43 | 77/16 | 4.73 (2.36; 9.46) | 0.61 (0.45; 0.77) | 2
Lamivudine, 100 mg/day, 24 weeks | HBV-DNA levels still detectable by branched-chain assay | 24/24 | 40/52 16/40 | 77/40 | 1.92 (1.28; 2.89) | 0.37 (0.18; 0.56) | 3
Lai, 2002^77^ Entecavir, 0.1 mg/day, 24 weeks | Entecavir, 0.5 mg/day, 24 weeks | HBV-DNA levels still detectable by branched-chain assay | 24/24 | 13/34 7/43 | 38/16 | 2.35 (1.05; 5.23) | 0.22 (0.02; 0.42) | 5
Lamivudine, 100 mg/day, 24 weeks | HBV-DNA levels still detectable by branched-chain assay | 24/24 | 13/34 16/40 | 38/40 | 0.96 (0.54; 1.69) | -0.02 (-0.24; 0.21) | -57
Lai, 2002^77^ Entecavir, 0.5 mg/day, 24 weeks | Lamivudine, 100 mg/day, 24 weeks | HBV-DNA levels still detectable by branched-chain assay | 24/24 | 7/43 16/40 | 16/40 | 0.41 (0.19; 0.89) | -0.24 (-0.42; -0.05) | -4
Lai, 2002^77^ Entecavir, 0.01 mg/day, 24 weeks | Entecavir, 0.1 mg/day, 24 weeks | HBeAg loss | 24/24 | 0/52 4/34 | 0/13 | 0.07 (0.00; 1.32) | -0.12 (-0.23; 0.00) | -8
Lai, 2002^77^ Entecavir, 0.01 mg/day, 24 weeks
Entecavir, 0.5 mg/day, 24 weeks | HBeAg loss | 24/24 | 0/52 0/43 | | | 0.00 (-0.04; 0.04)
Lamivudine, 100 mg/day, 24 weeks | HBeAg loss | 24/24 | 0/52 2/40 | 0/6 | 0.15 (0.01; 3.14) | -0.05 (-0.13; 0.03) | -20
Lai, 2002^77^ Entecavir, 0.1 mg/day, 24 weeks | Entecavir, 0.5 mg/day, 24 weeks | HBeAg loss | 24/24 | 4/34 0/43 | 13/0 | 11.31 (0.63; 203.14) | 0.12 (0.00; 0.23) | 8
Lamivudine, 100 mg/day, 24 weeks | HBeAg loss | 24/24 | 4/34 2/40 | 13/6 | 2.35 (0.46; 12.07) | 0.07 (-0.06; 0.20) | 15
Lai, 2002^77^ Entecavir, 0.5 mg/day, 24 weeks | Lamivudine, 100 mg/day, 24 weeks | HBeAg loss | 24/24 | 0/43 2/40 | 0/6 | 0.19 (0.01; 3.77) | -0.05 (-0.13; 0.03) | -20
Lai, 2002^77^ Entecavir, 0.01 mg/day, 24 weeks | Entecavir, 0.1 mg/day, 24 weeks | HBeAg seroconversion | 24/24 | 0/52 2/34 | 0/7 | 0.13 (0.01; 2.67) | -0.06 (-0.15; 0.03) | -17
Lai, 2002^77^ Entecavir, 0.01 mg/day, 24 weeks
Entecavir, 0.5 mg/day, 24 weeks | HBeAg seroconversion | 24/24 | 0/52 0/43 | | | 0.00 (-0.04; 0.04)
Lamivudine, 100 mg/day, 24 weeks | HBeAg seroconversion | 24/24 | 0/52 1/40 | 0/3 | 0.26 (0.01; 6.17) | -0.03 (-0.09; 0.04) | -40
Lai, 2002^77^ Entecavir, 0.1 mg/day, 24 weeks | Entecavir, 0.5 mg/day, 24 weeks | HBeAg seroconversion | 24/24 | 2/34 0/43 | 7/0 | 6.29 (0.31; 126.72) | 0.06 (-0.03; 0.15) | 17
Lamivudine, 100 mg/day, 24 weeks | HBeAg seroconversion | 24/24 | 2/34 1/40 | 7/3 | 2.35 (0.22; 24.83) | 0.03 (-0.06; 0.13) | 30
Lai, 2002^77^ Entecavir, 0.5 mg/day, 24 weeks | Lamivudine, 100 mg/day, 24 weeks | HBeAg seroconversion | 24/24 | 0/43 1/40 | 0/3 | 0.31 (0.01; 7.41) | -0.03 (-0.09; 0.04) | -40
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Normalization of ALT levels | 24/24 | 11/42 17/47 | 26/36 | 0.72 (0.38; 1.37) | -0.10 (-0.29; 0.09) | -10
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks
Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Normalization of ALT levels | 24/24 | 11/42 12/47 | 26/26 | 1.03 (0.51; 2.07) | 0.01 (-0.18; 0.19) | 152
Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Normalization of ALT levels | 24/24 | 11/42 7/45 | 26/16 | 1.68 (0.72; 3.94) | 0.11 (-0.06; 0.28) | 9
Chang, 2005^76^ Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Normalization of ALT levels | 24/24 | 17/47 12/47 | 36/26 | 1.42 (0.76; 2.63) | 0.11 (-0.08; 0.29) | 9
Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Normalization of ALT levels | 24/24 | 17/47 7/45 | 36/16 | 2.33 (1.07; 5.07) | 0.21 (0.03; 0.38) | 5
Chang, 2005^76^ Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Normalization of ALT levels | 24/24 | 12/47 7/45 | 26/16 | 1.64 (0.71; 3.79) | 0.10 (-0.06; 0.26) | 10
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Normalization of ALT levels | 48/48 | 19/42 17/47 | 45/36 | 1.25 (0.75; 2.07) | 0.09 (-0.11; 0.29) | 11
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks
Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Normalization of ALT levels | 48/48 | 19/42 14/47 | 45/30 | 1.52 (0.88; 2.63) | 0.15 (-0.04; 0.35) | 6
Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, 48 weeks | Normalization of ALT levels | 48/48 | 19/42 2/45 | 45/4 | 10.18 (2.52; 41.07) | 0.41 (0.25; 0.57) | 2
Chang, 2005^76^ Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Normalization of ALT levels | 48/48 | 17/47 14/47 | 36/30 | 1.21 (0.68; 2.17) | 0.06 (-0.13; 0.25) | 16
Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Normalization of ALT levels | 48/48 | 17/47 2/45 | 36/4 | 8.14 (1.99; 33.23) | 0.32 (0.17; 0.47) | 3
Chang, 2005^76^ Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Normalization of ALT levels | 48/48 | 14/47 2/45 | 30/4 | 6.70 (1.61; 27.84) | 0.25 (0.11; 0.40) | 4
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks | ALT levels >2 that at baseline and 10 times the ULN | 48/48 | 3/42 1/47 | 7/2 | 3.36 (0.36; 31.05) | 0.05 (-0.04; 0.14) | 20
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks
Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | ALT levels >2 that at baseline and 10 times the ULN | 48/48 | 3/42 2/47 | 7/4 | 1.68 (0.29; 9.56) | 0.03 (-0.07; 0.13) | 35
Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks | ALT levels >2 that at baseline and 10 times the ULN | 48/48 | 3/42 5/45 | 7/11 | 0.64 (0.16; 2.53) | -0.04 (-0.16; 0.08) | -25
Chang, 2005^76^ Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | ALT levels >2 that at baseline and 10 times the ULN | 48/48 | 1/47 2/47 | 2/4 | 0.50 (0.05; 5.33) | -0.02 (-0.09; 0.05) | -47
Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks | ALT levels >2 that at baseline and 10 times the ULN | 48/48 | 1/47 5/45 | 2/11 | 0.19 (0.02; 1.58) | -0.09 (-0.19; 0.01) | -11
Chang, 2005^76^ Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks | ALT levels >2 that at baseline and 10 times the ULN | 48/48 | 2/47 5/45 | 4/11 | 0.38 (0.08; 1.87) | -0.07 (-0.18; 0.04) | -15
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Death | 48/48 | 0/42 1/47 | 0/2 | 0.37 (0.02; 8.89) | -0.02 (-0.08; 0.04) | -47
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks
Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Death | 48/48 | 0/42 1/47 | 0/2 | 0.37 (0.02; 8.89) | -0.02 (-0.08; 0.04) | -47
Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Death | 48/48 | 0/42 0/45 | | | 0.00 (-0.04; 0.04)
Chang, 2005^76^ Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Death | 48/48 | 1/47 1/47 | 2/2 | 1.00 (0.06; 15.52) | 0.00 (-0.06; 0.06)
Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Death | 48/48 | 1/47 0/45 | 2/0 | 2.88 (0.12; 68.79) | 0.02 (-0.04; 0.08) | 47
Chang, 2005^76^ Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Death | 48/48 | 1/47 0/45 | 2/0 | 2.88 (0.12; 68.79) | 0.02 (-0.04; 0.08) | 47
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Death | 76/76 | 0/42 0/47 | | | 0.00 (-0.04; 0.04)
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks
Entecavir, 0.1 mg/ day after at least 24 weeks of lamivudine, total 48 weeks | Death | 76/76 | 0/42 0/47 | | | 0.00 (-0.04; 0.04)
Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Death | 76/76 | 0/42 0/45 | | | 0.00 (-0.04; 0.04)
Chang, 2005^76^ Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Death | 76/76 | 0/47 0/47 | | | 0.00 (-0.04; 0.04)
Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Death | 76/76 | 0/47 0/45 | | | 0.00 (-0.04; 0.04)
Chang, 2005^76^ Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Death | 76/76 | 0/47 0/45 | | | 0.00 (-0.04; 0.04)
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Any adverse event | 48/48 | 36/42 34/47 | 86/72 | 1.18 (0.96; 1.47) | 0.13 (-0.03; 0.30) | 7
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Headache | 48/48 | 10/42 12/47 | 24/26 | 0.93 (0.45; 1.93) | -0.02 (-0.20; 0.16) | -58
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Fatigue | 48/48 | 7/42 7/47 | 17/15 | 1.12 (0.43; 2.93) | 0.02 (-0.13; 0.17) | 56
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Pyrexia | 48/48 | 6/42 4/47 | 14/9 | 1.68 (0.51; 5.54) | 0.06 (-0.07; 0.19) | 17
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Bronchitis not otherwise specified | 48/48 | 5/42 1/47 | 12/2 | 5.60 (0.68; 45.98) | 0.10 (-0.01; 0.20) | 10
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Upper respiratory tract infection not otherwise specified | 48/48 | 4/42 4/47 | 10/9 | 1.12 (0.30; 4.20) | 0.01 (-0.11; 0.13) | 99
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Diarrhea not otherwise specified | 48/48 | 3/42 6/47 | 7/13 | 0.56 (0.15; 2.10) | -0.06 (-0.18; 0.07) | -18
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Upper abdominal pain | 48/48 | 3/42 2/47 | 7/4 | 1.68 (0.29; 9.56) | 0.03 (-0.07; 0.13) | 35
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Back pain | 48/48 | 2/42 9/47 | 5/19 | 0.25 (0.06; 1.09) | -0.14 (-0.27; -0.01) | -7
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Arthralgia | 48/48 | 2/42 7/47 | 5/15 | 0.32 (0.07; 1.46) | -0.10 (-0.22; 0.02) | -10
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Nasopharyngitis | 48/48 | 1/42 5/47 | 2/11 | 0.22 (0.03; 1.84) | -0.08 (-0.18; 0.02) | -12
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Any severe (grade 3–4) adverse event | 48/48 | 11/42 10/47 | 26/21 | 1.23 (0.58; 2.60) | 0.05 (-0.13; 0.23) | 20
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Any serious adverse event | 48/48 | 5/42 2/47 | 12/4 | 2.80 (0.57; 13.67) | 0.08 (-0.04; 0.19) | 13
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Discontinuations due to adverse events | 48/48 | 3/42 3/47 | 7/6 | 1.12 (0.24; 5.25) | 0.01 (-0.10; 0.11) | 132
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Increase in ALT>2 × baseline | 48/48 | 7/42 7/47 | 17/15 | 1.12 (0.43; 2.93) | 0.02 (-0.13; 0.17) | 56
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Increase in ALT>3 × baseline | 48/48 | 3/42 2/47 | 7/4 | 1.68 (0.29; 9.56) | 0.03 (-0.07; 0.13) | 35
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Any adverse event | 48/48 | 36/42 35/47 | 86/74 | 1.15 (0.93; 1.42) | 0.11 (-0.05; 0.28) | 9
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Headache | 48/48 | 10/42 13/47 | 24/28 | 0.86 (0.42; 1.75) | -0.04 (-0.22; 0.14) | -26
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Fatigue | 48/48 | 7/42 9/47 | 17/19 | 0.87 (0.36; 2.13) | -0.02 (-0.18; 0.13) | -40
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Pyrexia | 48/48 | 6/42 5/47 | 14/11 | 1.34 (0.44; 4.08) | 0.04 (-0.10; 0.17) | 27
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Bronchitis not otherwise specified | 48/48 | 5/42 0/47 | 12/0 | 12.28 (0.70; 215.63) | 0.12 (0.02; 0.22) | 8
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Upper respiratory tract infection not otherwise specified | 48/48 | 4/42 2/47 | 10/4 | 2.24 (0.43; 11.60) | 0.05 (-0.05; 0.16) | 19
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Diarrhea not otherwise specified | 48/48 | 3/42 5/47 | 7/11 | 0.67 (0.17; 2.64) | -0.03 (-0.15; 0.08) | -29
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Upper abdominal pain | 48/48 | 3/42 3/47 | 7/6 | 1.12 (0.24; 5.25) | 0.01 (-0.10; 0.11) | 132
Back pain | 48/48 | 2/42 2/47 | 5/4 | 1.12 (0.16; 7.60) | 0.01 (-0.08; 0.09) | 197
Arthralgia | 48/48 | 2/42 3/47 | 5/6 | 0.75 (0.13; 4.25) | -0.02 (-0.11; 0.08) | -62
Nasopharyngitis | 48/48 | 1/42 5/47 | 2/11 | 0.22 (0.03; 1.84) | -0.08 (-0.18; 0.02) | -12
Any severe (grade 3–4) adverse event | 48/48 | 11/42 11/47 | 26/23 | 1.12 (0.54; 2.31) | 0.03 (-0.15; 0.21) | 36
Any serious adverse event | 48/48 | 5/42 1/47 | 12/2 | 5.60 (0.68; 45.98) | 0.10 (-0.01; 0.20) | 10
Discontinuations due to adverse events | 48/48 | 3/42 3/47 | 7/6 | 1.12 (0.24; 5.25) | 0.01 (-0.10; 0.11) | 132
Increase in ALT >2 × baseline | 48/48 | 7/42 11/47 | 17/23 | 0.71 (0.30; 1.67) | -0.07 (-0.23; 0.10) | -15
Increase in ALT >3 × baseline | 48/48 | 3/42 4/47 | 7/9 | 0.84 (0.20; 3.54) | -0.01 (-0.13; 0.10) | -73
Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Any adverse event | 48/48 | 36/42 38/45 | 86/84 | 1.02 (0.85; 1.21) | 0.01 (-0.14; 0.16) | 79
Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks
Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Headache | 48/48 | 10/42 10/45 | 24/22 | 1.07 (0.50; 2.31) | 0.02 (-0.16; 0.19) | 63
Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks
Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Fatigue | 48/48 | 7/42 6/45 | 17/13 | 1.25 (0.46; 3.42) | 0.03 (-0.12; 0.18) | 30
Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks
Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Pyrexia | 48/48 | 6/42 3/45 | 14/7 | 2.14 (0.57; 8.03) | 0.08 (-0.05; 0.20) | 13
Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks
Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Bronchitis not otherwise specified | 48/48 | 5/42 2/45 | 12/4 | 2.68 (0.55; 13.07) | 0.07 (-0.04; 0.19) | 13
Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks
Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Upper respiratory tract infection not otherwise specified | 48/48 | 4/42 6/45 | 10/13 | 0.71 (0.22; 2.36) | -0.04 (-0.17; 0.10) | -26
Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks
Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Diarrhea not otherwise specified | 48/48 | 3/42 3/45 | 7/7 | 1.07 (0.23; 5.02) | 0.00 (-0.10; 0.11) | 210
Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks
Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Upper abdominal pain | 48/48 | 3/42 5/45 | 7/11 | 0.64 (0.16; 2.53) | -0.04 (-0.16; 0.08) | -25
Back pain | 48/48 | 2/42 3/45 | 5/7 | 0.71 (0.13; 4.07) | -0.02 (-0.12; 0.08) | -53
Arthralgia | 48/48 | 2/42 2/45 | 5/4 | 1.07 (0.16; 7.27) | 0.00 (-0.08; 0.09) | 315
Nasopharyngitis | 48/48 | 1/42 5/45 | 2/11 | 0.21 (0.03; 1.76) | -0.09 (-0.19; 0.02) | -11
Any severe (grade 3–4) adverse event | 48/48 | 11/42 9/45 | 26/20 | 1.31 (0.60; 2.84) | 0.06 (-0.12; 0.24) | 16
Any serious adverse event | 48/48 | 5/42 3/45 | 12/7 | 1.79 (0.45; 7.01) | 0.05 (-0.07; 0.17) | 19
Discontinuations due to adverse events | 48/48 | 3/42 4/45 | 7/9 | 0.80 (0.19; 3.38) | -0.02 (-0.13; 0.10) | -57
Increase in ALT>2 × baseline | 48/48 | 7/42 15/45 | 17/33 | 0.50 (0.23; 1.10) | -0.17 (-0.34; 0.01) | -6
Increase in ALT>3 × baseline | 48/48 | 3/42 6/45 | 7/13 | 0.54 (0.14; 2.01) | -0.06 (-0.19; 0.06) | -16
Chang, 2005^76^ Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Any adverse event | 48/48 | 34/47 35/47 | 72/74 | 0.97 (0.76; 1.24) | -0.02 (-0.20; 0.16) | -47
Chang, 2005^76^ Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks
Chang, 2005^76^ Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Headache | 48/48 | 12/47 13/47 | 26/28 | 0.92 (0.47; 1.81) | -0.02 (-0.20; 0.16) | -47
Chang, 2005^76^ Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks
Chang, 2005^76^ Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Fatigue | 48/48 | 7/47 9/47 | 15/19 | 0.78 (0.32; 1.92) | -0.04 (-0.19; 0.11) | -23
Chang, 2005^76^ Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks
Chang, 2005^76^ Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Pyrexia | 48/48 | 4/47 5/47 | 9/11 | 0.80 (0.23; 2.80) | -0.02 (-0.14; 0.10) | -47
Chang, 2005^76^ Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks
Chang, 2005^76^ Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Bronchitis not otherwise specified | 48/48 | 1/47 0/47 | 2/0 | 3.00 (0.13; 71.82) | 0.02 (-0.04; 0.08) | 47
Chang, 2005^76^ Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks
Chang, 2005^76^ Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Upper respiratory tract infection not otherwise specified | 48/48 | 4/47 2/47 | 9/4 | 2.00 (0.38; 10.40) | 0.04 (-0.06; 0.14) | 23
Chang, 2005^76^ Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks
Chang, 2005^76^ Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Diarrhea not otherwise specified | 48/48 | 6/47 5/47 | 13/11 | 1.20 (0.39; 3.66) | 0.02 (-0.11; 0.15) | 47
Chang, 2005^76^ Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks
Chang, 2005^76^ Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Upper abdominal pain | 48/48 | 2/47 3/47 | 4/6 | 0.67 (0.12; 3.81) | -0.02 (-0.11; 0.07) | -47
Chang, 2005^76^ Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks
Chang, 2005^76^ Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Back pain | 48/48 | 9/47 2/47 | 19/4 | 4.50 (1.03; 19.73) | 0.15 (0.02; 0.28) | 7
Chang, 2005^76^ Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks
Chang, 2005^76^ Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Arthralgia | 48/48 | 7/47 3/47 | 15/6 | 2.33 (0.64; 8.48) | 0.09 (-0.04; 0.21) | 12
Chang, 2005^76^ Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks
Chang, 2005^76^ Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Nasopharyngitis | 48/48 | 5/47 5/47 | 11/11 | 1.00 (0.31; 3.23) | 0.00 (-0.12; 0.12)
Chang, 2005^76^ Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks
Chang, 2005^76^ Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Any severe (grade 3–4) adverse event | 48/48 | 10/47 11/47 | 21/23 | 0.91 (0.43; 1.93) | -0.02 (-0.19; 0.15) | -47
Chang, 2005^76^ Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks
Chang, 2005^76^ Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Any serious adverse event | 48/48 | 2/47 1/47 | 4/2 | 2.00 (0.19; 21.31) | 0.02 (-0.05; 0.09) | 47
Chang, 2005^76^ Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks
Chang, 2005^76^ Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Discontinuations due to adverse events | 48/48 | 3/47 3/47 | 6/6 | 1.00 (0.21; 4.70) | 0.00 (-0.10; 0.10)
Chang, 2005^76^ Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks
Chang, 2005^76^ Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Increase in ALT >2 × baseline | 48/48 | 7/47 11/47 | 15/23 | 0.64 (0.27; 1.50) | -0.09 (-0.24; 0.07) | -12
Chang, 2005^76^ Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks
Chang, 2005^76^ Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Increase in ALT >3 × baseline | 48/48 | 2/47 4/47 | 4/9 | 0.50 (0.10; 2.60) | -0.04 (-0.14; 0.06) | -23
Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Any adverse event | 48/48 | 34/47 38/45 | 72/84 | 0.86 (0.69; 1.06) | -0.12 (-0.29; 0.04) | -8
Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks
Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Headache | 48/48 | 12/47 10/45 | 26/22 | 1.15 (0.55; 2.39) | 0.03 (-0.14; 0.21) | 30
Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks
Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Fatigue | 48/48 | 7/47 6/45 | 15/13 | 1.12 (0.41; 3.07) | 0.02 (-0.13; 0.16) | 64
Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks
Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Pyrexia | 48/48 | 4/47 3/45 | 9/7 | 1.28 (0.30; 5.39) | 0.02 (-0.09; 0.13) | 54
Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks
Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Bronchitis not otherwise specified | 48/48 | 1/47 2/45 | 2/4 | 0.48 (0.04; 5.10) | -0.02 (-0.10; 0.05) | -43
Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks
Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Upper respiratory tract infection not otherwise specified | 48/48 | 4/47 6/45 | 9/13 | 0.64 (0.19; 2.11) | -0.05 (-0.18; 0.08) | -21
Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks
Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Diarrhea not otherwise specified | 48/48 | 6/47 3/45 | 13/7 | 1.91 (0.51; 7.20) | 0.06 (-0.06; 0.18) | 16
Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks
Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Upper abdominal pain | 48/48 | 2/47 5/45 | 4/11 | 0.38 (0.08; 1.87) | -0.07 (-0.18; 0.04) | -15
Back pain | 48/48 | 9/47 3/45 | 19/7 | 2.87 (0.83; 9.94) | 0.12 (-0.01; 0.26) | 8
Arthralgia | 48/48 | 7/47 2/45 | 15/4 | 3.35 (0.73; 15.28) | 0.10 (-0.01; 0.22) | 10
Nasopharyngitis | 48/48 | 5/47 5/45 | 11/11 | 0.96 (0.30; 3.09) | 0.00 (-0.13; 0.12) | -212
Any severe (grade 3–4) adverse event | 48/48 | 10/47 9/45 | 21/20 | 1.06 (0.48; 2.37) | 0.01 (-0.15; 0.18) | 78
Any serious adverse event | 48/48 | 2/47 3/45 | 4/7 | 0.64 (0.11; 3.64) | -0.02 (-0.12; 0.07) | -41
Discontinuations due to adverse events | 48/48 | 3/47 4/45 | 6/9 | 0.72 (0.17; 3.03) | -0.03 (-0.13; 0.08) | -40
Increase in ALT >2 × baseline | 48/48 | 7/47 15/45 | 15/33 | 0.45 (0.20; 0.99) | -0.18 (-0.36; -0.01) | -5
Increase in ALT >3 × baseline | 48/48 | 2/47 6/45 | 4/13 | 0.32 (0.07; 1.50) | -0.09 (-0.21; 0.02) | -11
Chang, 2005^76^ Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Any adverse event | 48/48 | 35/47 38/45 | 74/84 | 0.88 (0.72; 1.09) | -0.10 (-0.26; 0.06) | -10
Chang, 2005^76^ Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Headache | 48/48 | 13/47 10/45 | 28/22 | 1.24 (0.61; 2.55) | 0.05 (-0.12; 0.23) | 18
Chang, 2005^76^ Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Fatigue | 48/48 | 9/47 6/45 | 19/13 | 1.44 (0.56; 3.71) | 0.06 (-0.09; 0.21) | 17
Chang, 2005^76^ Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Pyrexia | 48/48 | 5/47 3/45 | 11/7 | 1.60 (0.40; 6.29) | 0.04 (-0.07; 0.15) | 25
Chang, 2005^76^ Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Bronchitis not otherwise specified | 48/48 | 0/47 2/45 | 0/4 | 0.19 (0.01; 3.89) | -0.04 (-0.12; 0.03) | -23
Chang, 2005^76^ Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Upper respiratory tract infection not otherwise specified | 48/48 | 2/47 6/45 | 4/13 | 0.32 (0.07; 1.50) | -0.09 (-0.21; 0.02) | -11
Chang, 2005^76^ Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Diarrhea not otherwise specified | 48/48 | 5/47 3/45 | 11/7 | 1.60 (0.40; 6.29) | 0.04 (-0.07; 0.15) | 25
Chang, 2005^76^ Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Upper abdominal pain | 48/48 | 3/47 5/45 | 6/11 | 0.57 (0.15; 2.26) | -0.05 (-0.16; 0.07) | -21
Chang, 2005^76^ Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Back pain | 48/48 | 2/47 3/45 | 4/7 | 0.64 (0.11; 3.64) | -0.02 (-0.12; 0.07) | -41
Chang, 2005^76^ Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Arthralgia | 48/48 | 3/47 2/45 | 6/4 | 1.44 (0.25; 8.20) | 0.02 (-0.07; 0.11) | 52
Chang, 2005^76^ Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Nasopharyngitis | 48/48 | 5/47 5/45 | 11/11 | 0.96 (0.30; 3.09) | 0.00 (-0.13; 0.12) | -212
Chang, 2005^76^ Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Any severe (grade 3–4) adverse event | 48/48 | 11/47 9/45 | 23/20 | 1.17 (0.54; 2.55) | 0.03 (-0.13; 0.20) | 29
Chang, 2005^76^ Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Any serious adverse event | 48/48 | 1/47 3/45 | 2/7 | 0.32 (0.03; 2.96) | -0.05 (-0.13; 0.04) | -22
Chang, 2005^76^ Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Discontinuations due to adverse events | 48/48 | 3/47 4/45 | 6/9 | 0.72 (0.17; 3.03) | -0.03 (-0.13; 0.08) | -40
Chang, 2005^76^ Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Increase in ALT >2 × baseline | 48/48 | 11/47 15/45 | 23/33 | 0.70 (0.36; 1.36) | -0.10 (-0.28; 0.08) | -10
Increase in ALT >3 × baseline | 48/48 | 4/47 6/45 | 9/13 | 0.64 (0.19; 2.11) | -0.05 (-0.18; 0.08) | -21
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Any adverse event | 76/76 | 8/42 9/47 | 19/19 | 0.99 (0.42; 2.34) | 0.00 (-0.16; 0.16) | -987
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Any severe (grade 3–4) adverse event | 76/76 | 2/42 1/47 | 5/2 | 2.24 (0.21; 23.80) | 0.03 (-0.05; 0.10) | 38
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Any serious adverse event | 76/76 | 0/42 0/47 | | | 0.00 (-0.04; 0.04)
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Increase in ALT >2 × baseline | 76/76 | 7/42 8/47 | 17/17 | 0.98 (0.39; 2.47) | 0.00 (-0.16; 0.15) | -282
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Increase in ALT>3 × baseline | 76/76 | 6/42 4/47 | 14/9 | 1.68 (0.51; 5.54) | 0.06 (-0.07; 0.19) | 17
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Any adverse event | 76/76 | 8/42 5/47 | 19/11 | 1.79 (0.63; 5.05) | 0.08 (-0.06; 0.23) | 12
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Any severe (grade 3–4) adverse event | 76/76 | 2/42 2/47 | 5/4 | 1.12 (0.16; 7.60) | 0.01 (-0.08; 0.09) | 197
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Any serious adverse event | 76/76 | 0/42 1/47 | 0/2 | 0.37 (0.02; 8.89) | -0.02 (-0.08; 0.04) | -47
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Increase in ALT >2 × baseline | 76/76 | 7/42 9/47 | 17/19 | 0.87 (0.36; 2.13) | -0.02 (-0.18; 0.13) | -40
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Increase in ALT >3 × baseline | 76/76 | 6/42 6/47 | 14/13 | 1.12 (0.39; 3.21) | 0.02 (-0.13; 0.16) | 66
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Any adverse event | 76/76 | 8/42 5/45 | 19/11 | 1.71 (0.61; 4.83) | 0.08 (-0.07; 0.23) | 13
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Any severe (grade 3–4) adverse event | 76/76 | 2/42 1/45 | 5/2 | 2.14 (0.20; 22.77) | 0.03 (-0.05; 0.10) | 39
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Any serious adverse event | 76/76 | 0/42 2/45 | 0/4 | 0.21 (0.01; 4.33) | -0.04 (-0.12; 0.03) | -23
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Increase in ALT >2 × baseline | 76/76 | 7/42 3/45 | 17/7 | 2.50 (0.69; 9.04) | 0.10 (-0.03; 0.23) | 10
Increase in ALT >3 × baseline | 76/76 | 6/42 2/45 | 14/4 | 3.21 (0.69; 15.05) | 0.10 (-0.02; 0.22) | 10
Chang, 2005^76^ Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Any adverse event | 76/76 | 9/47 5/47 | 19/11 | 1.80 (0.65; 4.97) | 0.09 (-0.06; 0.23) | 12
Chang, 2005^76^ Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Any severe (grade 3–4) adverse event | 76/76 | 1/47 2/47 | 2/4 | 0.50 (0.05; 5.33) | -0.02 (-0.09; 0.05) | -47
Chang, 2005^76^ Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Any serious adverse event | 76/76 | 0/47 1/47 | 0/2 | 0.33 (0.01; 7.98) | -0.02 (-0.08; 0.04) | -47
Chang, 2005^76^ Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Increase in ALT >2 × baseline | 76/76 | 8/47 9/47 | 17/19 | 0.89 (0.38; 2.11) | -0.02 (-0.18; 0.13) | -47
Chang, 2005^76^ Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Increase in ALT >3 × baseline | 76/76 | 4/47 6/47 | 9/13 | 0.67 (0.20; 2.21) | -0.04 (-0.17; 0.08) | -23
Chang, 2005^76^ Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Any adverse event | 76/76 | 9/47 5/45 | 19/11 | 1.72 (0.63; 4.75) | 0.08 (-0.06; 0.23) | 12
Chang, 2005^76^ Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Any severe (grade 3–4) adverse event | 76/76 | 1/47 1/45 | 2/2 | 0.96 (0.06; 14.85) | 0.00 (-0.06; 0.06) | -1058
Chang, 2005^76^ Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Any serious adverse event | 76/76 | 0/47 2/45 | 0/4 | 0.19 (0.01; 3.89) | -0.04 (-0.12; 0.03) | -23
Chang, 2005^76^ Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Increase in ALT >2 × baseline | 76/76 | 8/47 3/45 | 17/7 | 2.55 (0.72; 9.02) | 0.10 (-0.03; 0.23) | 10
Increase in ALT >3 × baseline | 76/76 | 4/47 2/45 | 9/4 | 1.91 (0.37; 9.95) | 0.04 (-0.06; 0.14) | 25
Chang, 2005^76^ Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Any adverse event | 76/76 | 5/47 5/45 | 11/11 | 0.96 (0.30; 3.09) | 0.00 (-0.13; 0.12) | -212
Chang, 2005^76^ Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Any severe (grade 3–4) adverse event | 76/76 | 2/47 1/45 | 4/2 | 1.91 (0.18; 20.39) | 0.02 (-0.05; 0.09) | 49
Chang, 2005^76^ Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Any serious adverse event | 76/76 | 1/47 2/45 | 2/4 | 0.48 (0.04; 5.10) | -0.02 (-0.10; 0.05) | -43
Chang, 2005^76^ Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Increase in ALT >2 × baseline | 76/76 | 9/47 3/45 | 19/7 | 2.87 (0.83; 9.94) | 0.12 (-0.01; 0.26) | 8
Increase in ALT >3 × baseline | 76/76 | 6/47 2/45 | 13/4 | 2.87 (0.61; 13.50) | 0.08 (-0.03; 0.20) | 12
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks | HBV DNA loss by bDNA assay | 24/24 | 33/42 24/47 | 79/51 | 1.54 (1.12; 2.12) | 0.28 (0.09; 0.46) | 4
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | HBV DNA loss by bDNA assay | 24/24 | 33/42 9/47 | 79/19 | 4.10 (2.23; 7.54) | 0.59 (0.43; 0.76) | 2
Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks | HBV DNA loss by bDNA assay | 24/24 | 33/42 6/45 | 79/13 | 5.89 (2.75; 12.62) | 0.65 (0.49; 0.81) | 2
Chang, 2005^76^ Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, 48 weeks | Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | HBV DNA loss by bDNA assay | 24/24 | 24/47 9/47 | 51/19 | 2.67 (1.39; 5.11) | 0.32 (0.14; 0.50) | 3
Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, 48 weeks | HBV DNA by bDNA assay | 24/24 | 24/47 6/45 | 51/13 | 3.83 (1.73; 8.49) | 0.38 (0.20; 0.55) | 3
Chang, 2005^76^ Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks | HBV DNA by bDNA assay | 24/24 | 9/47 6/45 | 19/13 | 1.44 (0.56; 3.71) | 0.06 (-0.09; 0.21) | 17
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks | HBV DNA <400 copies/mL | 24/24 | 7/42 4/47 | 17/9 | 1.96 (0.62; 6.22) | 0.08 (-0.06; 0.22) | 12
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | HBV DNA <400 copies/mL | 24/24 | 7/42 0/47 | 17/0 | 16.74 (0.99; 284.58) | 0.17 (0.05; 0.28) | 6
Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks | HBV DNA <400 copies/mL | 24/24 | 7/42 1/45 | 17/2 | 7.50 (0.96; 58.41) | 0.14 (0.02; 0.27) | 7
Chang, 2005^76^ Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | HBV DNA <400 copies/mL | 24/24 | 4/47 0/47 | 9/0 | 9.00 (0.50; 162.62) | 0.09 (0.00; 0.17) | 12
Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks | HBV DNA <400 copies/mL | 24/24 | 4/47 1/45 | 9/2 | 3.83 (0.44; 32.97) | 0.06 (-0.03; 0.15) | 16
Chang, 2005^76^ Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks | HBV DNA <400 copies/mL | 24/24 | 0/47 1/45 | 0/2 | 0.32 (0.01; 7.64) | -0.02 (-0.08; 0.04) | -45
Chang, 2005^76^ entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks | HBV DNA <400 copies/mL | 48/48 | 11/42 12/47 | 26/26 | 1.03 (0.51; 2.07) | 0.01 (-0.18; 0.19) | 152
Chang, 2005^76^ entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | HBV DNA <400 copies/mL | 48/48 | 11/42 2/47 | 26/4 | 6.15 (1.45; 26.19) | 0.22 (0.07; 0.36) | 5
Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks | HBV DNA <400 copies/mL | 48/48 | 11/42 2/45 | 26/4 | 5.89 (1.39; 25.04) | 0.22 (0.07; 0.36) | 5
Chang, 2005^76^ entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.1 mg/ day after at least 24 weeks of lamivudine, total 48 weeks | HBV DNA <400 copies/mL | 48/48 | 12/47 2/47 | 26/4 | 6.00 (1.42; 25.36) | 0.21 (0.08; 0.35) | 5
Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks | HBV DNA <400 copies/mL | 48/48 | 12/47 2/45 | 26/4 | 5.74 (1.36; 24.25) | 0.21 (0.07; 0.35) | 5
Chang, 2005^76^ entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, total 48 weeks | HBV DNA <400 copies/mL | 48/48 | 2/47 2/45 | 4/4 | 0.96 (0.14; 6.51) | 0.00 (-0.09; 0.08) | -529
Sherman, 2006^75^ Entecavir, 1 mg/day, 63 weeks | Lamivudine, 100, 52 weeks | ALT normalization (<1.0 × ULN) | 63/52 | 86/141 22/145 | 61/15 | 4.02 (2.68; 6.04) | 0.46 (0.36; 0.56) | 2
Sherman, 2006^75^ Entecavir, 1 mg/day, 63 weeks | Lamivudine, 100, 52 weeks | ALT flares | 63/52 | 1/141 16/145 | 1/11 | 0.06 (0.01; 0.48) | -0.10 (-0.16; -0.05) | -10
Sherman, 2006^75^ Entecavir, 1 mg/day, 63 weeks | Lamivudine, 100, 52 weeks | Death | 48/48 | 0/141 1/145 | 0/1 | 0.34 (0.01; 8.34) | -0.01 (-0.03; 0.01) | -145
Sherman, 2006^75^ Entecavir, 1 mg/day, 63 weeks | Lamivudine, 100, 52 weeks | Deaths | 63/52 | 1/141 2/145 | 1/1 | 0.51 (0.05; 5.61) | -0.01 (-0.03; 0.02) | -149
Sherman, 2006^75^ Entecavir, 1 mg/day, 63 weeks | Lamivudine, 100, 52 weeks | Treatment failure as no response. Response was defined as histological improvement, (>2-point decrease in the Knodell necroinflammatory score and no worsening of the Knodell fibrosis score); serum HBV DNA <0.7 MEq/mL by bDNA assay and ALT <1.25 ULN | 48/48 | 0/141 2/145 | 0/1 | 0.21 (0.01; 4.25) | -0.01 (-0.04; 0.01) | -73
Sherman, 2006^75^ Entecavir, 1 mg/day, 63 weeks | Lamivudine, 100, 52 weeks | HBV DNA <0.7 MEq/mL by bDNA and ALT <1.25 × ULN | 63/52 | 77/141 6/145 | 55/4 | 13.20 (5.94; 29.31) | 0.50 (0.42; 0.59) | 2
Sherman, 2006^75^ Entecavir, 1 mg/day, 63 weeks | Lamivudine, 100, 52 weeks | Adverse events | 48/48 | 1/141 8/145 | 1/6 | 0.13 (0.02; 1.01) | -0.05 (-0.09; -0.01) | -21
Sherman, 2006^75^ Entecavir, 1 mg/day, 63 weeks | Lamivudine, 100, 52 weeks | Any adverse event | 63/52 | 120/141 117/145 | 85/81 | 1.05 (0.95; 1.17) | 0.04 (-0.04; 0.13) | 23
Sherman, 2006^75^ Entecavir, 1 mg/day, 63 weeks | Lamivudine, 100, 52 weeks | Serious adverse events | 63/52 | 14/141 11/145 | 10/8 | 1.31 (0.62; 2.78) | 0.02 (-0.04; 0.09) | 43
Sherman, 2006^75^ Entecavir, 1 mg/day, 63 weeks | Lamivudine, 100, 52 weeks | Discontinuations because of adverse events | 63/52 | 2/141 10/145 | 1/7 | 0.21 (0.05; 0.92) | -0.05 (-0.10; -0.01) | -18
Sherman, 2006^75^ Entecavir, 1 mg/day, 63 weeks | Lamivudine, 100, 52 weeks | Improvement of 2 points in the necroinflammatory component of the Knodell score with no worsening in the fibrosis component of the score | 63/52 | 68/141 32/145 | 48/22 | 2.19 (1.54; 3.10) | 0.26 (0.16; 0.37) | 4
Sherman, 2006^75^ Entecavir, 1 mg/day, 63 weeks | Lamivudine, 100, 52 weeks | No histological improvement | 63/52 | 42/141 66/145 | 30/46 | 0.65 (0.48; 0.89) | -0.16 (-0.27; -0.05) | -6
Sherman, 2006^75^ Entecavir, 1 mg/day, 63 weeks | Lamivudine, 100, 52 weeks | Improvement in Ishak fibrosis | 63/52 | 42/141 19/145 | 30/13 | 2.27 (1.39; 3.71) | 0.17 (0.07; 0.26) | 6
Sherman, 2006^75^ Entecavir, 1 mg/day, 63 weeks | Lamivudine, 100, 52 weeks | No change in Ishak fibrosis | 63/52 | 54/141 49/145 | 38/34 | 1.13 (0.83; 1.54) | 0.05 (-0.07; 0.16) | 22
Sherman, 2006^75^ Entecavir, 1 mg/day, 63 weeks | Lamivudine, 100, 52 weeks | Worsening in Ishak fibrosis | 63/52 | 14/141 30/145 | 10/21 | 0.48 (0.27; 0.87) | -0.11 (-0.19; -0.03) | -9
Sherman, 2006^75^ Entecavir, 1 mg/day, 63 weeks | Lamivudine, 100, 52 weeks | HBV DNA <300 copies/mL by PCR | 63/52 | 27/141 2/145 | 19/1 | 13.88 (3.36; 57.29) | 0.18 (0.11; 0.25) | 6
Sherman, 2006^75^ Entecavir, 1 mg/day, 63 weeks | Lamivudine, 100, 52 weeks | Loss of HBeAg | 63/52 | 14/141 5/145 | 10/3 | 2.88 (1.07; 7.78) | 0.06 (0.01; 0.12) | 15
Sherman, 2006^75^ Entecavir, 1 mg/day, 63 weeks | Lamivudine, 100, 52 weeks | HBeAg seroconversion | 63/52 | 11/141 4/145 | 8/3 | 2.83 (0.92; 8.67) | 0.05 (0.00; 0.10) | 20
Sherman, 2006^75^ Entecavir, 1 mg/day, 63 weeks | Lamivudine, 100, 52 weeks | HBV DNA <0.7 MEq/mL without HBeAg loss | 63/52 | 80/141 7/145 | 57/5 | 11.75 (5.62; 24.56) | 0.52 (0.43; 0.61) | 2
Sherman, 2006^75^ Entecavir, 1 mg/day, 63 weeks | Lamivudine, 100, 52 weeks | No response (HBV DNA >0.7 MEq/mL) | 63/52 | 40/141 121/145 | 28/83 | 0.34 (0.26; 0.45) | -0.55 (-0.65; -0.45) | -2
HBV DNA <0.7 MEq/mL and HBeAg loss | 87/76 | 5/141 1/145 | 4/1 | 5.14 (0.61; 43.46) | 0.03 (0.00; 0.06) | 35
Gish, 2007^101^ entecavir, 0.5 mg/day, 96 weeks | Lamivudine, 100 mg/day, 96 weeks | ALT normalization (<1 ULN) | 48/48 | 161/243 116/165 | 66/70 | 0.94 (0.82; 1.08) | -0.04 (-0.13; 0.05) | -25
Gish, 2007^101^ entecavir, 0.5 mg/day, 96 weeks | Lamivudine, 100 mg/day, 96 weeks | ALT normalization (<1 ULN) | 96/96 | 193/243 112/165 | 79/68 | 1.17 (1.03; 1.32) | 0.12 (0.03; 0.20) | 9
Gish, 2007^101^ entecavir, 0.5 mg/day, 96 weeks | Lamivudine, 100 mg/day, 96 weeks | ALT normalization (<1 ULN) | 96/96 | 307/354 280/355 | 87/79 | 1.10 (1.03; 1.18) | 0.08 (0.02; 0.13) | 13
Gish, 2007^101^ entecavir, 0.5 mg/day, 96 weeks | Lamivudine, 100 mg/day, 96 weeks | ALT levels >2 baseline and 10 × the ULN) | 96/96 | 11/354 25/355 | 3/7 | 0.44 (0.22; 0.88) | -0.04 (-0.07; -0.01) | -25
Gish, 2007^101^ entecavir, 0.5 mg/day, 96 weeks | Lamivudine, 100 mg/day, 96 weeks | Liver decompensation | 96/96 | 0/354 1/355 | | 0.33 (0.01; 8.18) | 0.00 (-0.01; 0.00) | -355
Gish, 2007^101^ entecavir, 0.5 mg/day, 96 weeks | Lamivudine, 100 mg/day, 96 weeks | Death | 120/120 | 2/354 4/355 | 1/1 | 0.50 (0.09; 2.72) | -0.01 (-0.02; 0.01) | -178
Gish, 2007^101^ entecavir, 0.5 mg/day, 96 weeks | Lamivudine, 100 mg/day, 96 weeks | Death | 96/96 | 0/354 2/355 | 0/1 | 0.20 (0.01; 4.16) | -0.01 (-0.02; 0.00) | -178
Gish, 2007^101^ entecavir, 0.5 mg/day, 96 weeks | Lamivudine, 100 mg/day, 96 weeks | Discontinuation due to adverse effect | 96/96 | 1/243 9/165 | 0/5 | 0.08 (0.01; 0.59) | -0.05 (-0.09; -0.01) | -20
Gish, 2007^101^ entecavir, 0.5 mg/day, 96 weeks | Lamivudine, 100 mg/day, 96 weeks | Serious adverse events | 96/96 | 28/354 28/355 | 8/8 | 1.00 (0.61; 1.66) | 0.00 (-0.04; 0.04) | 4488
Gish, 2007^101^ entecavir, 0.5 mg/day, 96 weeks | Lamivudine, 100 mg/day, 96 weeks | Any adverse effect | 96/96 | 308/354 298/355 | 87/84 | 1.04 (0.98; 1.10) | 0.03 (-0.02; 0.08) | 33
Gish, 2007^101^ entecavir, 0.5 mg/day, 96 weeks | Lamivudine, 100 mg/day, 96 weeks | Any adverse effect | 120/120 | 92/243 85/165 | 38/52 | 0.73 (0.59; 0.91) | -0.14 (-0.23; -0.04) | -7
Gish, 2007^101^ entecavir, 0.5 mg/day, 96 weeks | Lamivudine, 100 mg/day, 96 weeks | Serious adverse events | 144/144 | 9/243 11/165 | 4/7 | 0.56 (0.24; 1.31) | -0.03 (-0.07; 0.02) | -34
Gish, 2007^101^ entecavir, 0.5 mg/day, 96 weeks | Lamivudine, 100 mg/day, 96 weeks | HBV DNA level <300 copies/mL (57 IU/mL) by PCR assay | 48/48 | 156/243 66/165 | 64/40 | 1.60 (1.30; 1.98) | 0.24 (0.15; 0.34) | 4
Gish, 2007^101^ entecavir, 0.5 mg/day, 96 weeks | Lamivudine, 100 mg/day, 96 weeks | HBV DNA level <300 copies/mL (57 IU/mL) by PCR assay | 96/96 | 180/243 60/165 | 74/36 | 2.04 (1.64; 2.53) | 0.38 (0.29; 0.47) | 3
Gish, 2007^101^ entecavir, 0.5 mg/day, 96 weeks | Lamivudine, 100 mg/day, 96 weeks | HBeAg seroconversion | 96/96 | 26/243 20/165 | 11/12 | 0.88 (0.51; 1.53) | -0.01 (-0.08; 0.05) | -70
Gish, 2007^101^ entecavir, 0.5 mg/day, 96 weeks | Lamivudine, 100 mg/day, 96 weeks | HBV DNA levels <0.7 MEq/mL and loss of HBeAg | 96/96 | 111/354 93/355 | 31/26 | 1.20 (0.95; 1.51) | 0.05 (-0.01; 0.12) | 19
Gish, 2007^101^ entecavir, 0.5 mg/day, 96 weeks | Lamivudine, 100 mg/day, 96 weeks | HBV DNA levels <0.7 MEq/mL but HBeAg+ | 96/96 | 202/354 86/355 | 57/24 | 2.36 (1.92; 2.89) | 0.33 (0.26; 0.40) | 3
Gish, 2007^101^ entecavir, 0.5 mg/day, 96 weeks | Lamivudine, 100 mg/day, 96 weeks | HBV DNA levels >105 copies/mL | 96/96 | 5/243 43/165 | 2/26 | 0.08 (0.03; 0.20) | -0.24 (-0.31; -0.17) | -4
Gish, 2007^101^ entecavir, 0.5 mg/day, 96 weeks | Lamivudine, 100 mg/day, 96 weeks | HBV DNA level <300 copies/mL (57 IU/mL) by PCR | 96/96 | 284/354 137/355 | 80/39 | 2.08 (1.81; 2.39) | 0.42 (0.35; 0.48) | 2
Gish, 2007^101^ entecavir, 0.5 mg/day, 96 weeks | Lamivudine, 100 mg/day, 96 weeks | HBeAg seroconversion | 96/96 | 110/243 92/165 | 45/56 | 0.81 (0.67; 0.99) | -0.10 (-0.20; -0.01) | -10
Gish, 2007^101^ entecavir, 0.5 mg/day, 96 weeks | Lamivudine, 100 mg/day, 96 weeks | HBsAg loss | 96/96 | 18/243 10/165 | 7/6 | 1.22 (0.58; 2.58) | 0.01 (-0.04; 0.06) | 74
Gish, 2007^101^ entecavir, 0.5 mg/day, 96 weeks | Lamivudine, 100 mg/day, 96 weeks | HBsAg seroconversion | 96/96 | 6/243 8/165 | 2/5 | 0.51 (0.18; 1.44) | -0.02 (-0.06; 0.01) | -42
Virologic break through (1 log10 increase in HBV DNA level above nadir by PCR, as determined by 2 sequential measurements or last on-treatment measurement) | 96/96 | 13/354 0/355 | 4/0 | 27.08 (1.62; 453.72) | 0.04 (0.02; 0.06) | 27
Chang, 2006^73^ Entecavir (Baraclude, Bristol-Myers Squibb), 0.5 mg/day, 52 weeks | Lamivudine (Epivir-HBV, GlaxoSmithKline), 100 mg/day, 52 weeks | ALT normalization (≤1× ULN) | 52/52 | 242/354 213/355 | 68/60 | 1.14 (1.02; 1.27) | 0.08 (0.01; 0.15) | 12
Chang, 2006^73^ Entecavir (Baraclude, Bristol-Myers Squibb), 0.5 mg/day, 52 weeks | Lamivudine (Epivir-HBV, GlaxoSmithKline), 100 mg/day, 52 weeks | ALT >2× baseline and >10 × ULN | 52/52 | 12/354 23/355 | 3/6 | 0.52 (0.26; 1.04) | -0.03 (-0.06; 0.00) | -32
Chang, 2006^73^ Entecavir (Baraclude, Bristol-Myers Squibb), 0.5 mg/day, 52 weeks | Lamivudine (Epivir-HBV, GlaxoSmithKline), 100 mg/day, 52 weeks | ALT >2 × reference value and >10 × ULN | 76/76 | 2/354 9/355 | 1/3 | 0.22 (0.05; 1.02) | -0.02 (-0.04; 0.00) | -51
Chang, 2006^73^ Entecavir (Baraclude, Bristol-Myers Squibb), 0.5 mg/day, 52 weeks | Lamivudine (Epivir-HBV, GlaxoSmithKline), 100 mg/day, 52 weeks | Death | 52/52 | 0/354 2/355 | 0/1 | 0.20 (0.01; 4.16) | -0.01 (-0.02; 0.00) | -178
Chang, 2006^73^ Entecavir (Baraclude, Bristol-Myers Squibb), 0.5 mg/day, 52 weeks | Lamivudine (Epivir-HBV, GlaxoSmithKline), 100 mg/day, 52 weeks | Hepatic decompensation | 76/76 | 0/354 1/355 | | 0.33 (0.01; 8.18) | 0.00 (-0.01; 0.00) | -355
Chang, 2006^73^ Entecavir (Baraclude, Bristol-Myers Squibb), 0.5 mg/day, 52 weeks | Lamivudine (Epivir-HBV, GlaxoSmithKline), 100 mg/day, 52 weeks | Undetectable HBV DNA by PCR and normal ALT | 76/76 | 51/354 40/355 | 14/11 | 1.28 (0.87; 1.88) | 0.03 (-0.02; 0.08) | 32
Chang, 2006^73^ Entecavir (Baraclude, Bristol-Myers Squibb), 0.5 mg/day, 52 weeks | Lamivudine (Epivir-HBV, GlaxoSmithKline), 100 mg/day, 52 weeks | Discontinuation due to adverse events | 52/52 | 1/354 9/355 | 0/3 | 0.11 (0.01; 0.87) | -0.02 (-0.04; -0.01) | -44
Chang, 2006^73^ Entecavir (Baraclude, Bristol-Myers Squibb), 0.5 mg/day, 52 weeks | Lamivudine (Epivir-HBV, GlaxoSmithKline), 100 mg/day, 52 weeks | Any adverse event | 52/52 | 306/354 297/355 | 86/84 | 1.03 (0.97; 1.10) | 0.03 (-0.02; 0.08) | 36
Chang, 2006^73^ Entecavir (Baraclude, Bristol-Myers Squibb), 0.5 mg/day, 52 weeks | Lamivudine (Epivir-HBV, GlaxoSmithKline), 100 mg/day, 52 weeks | Serious adverse event | 52/52 | 27/354 30/355 | 8/8 | 0.90 (0.55; 1.49) | -0.01 (-0.05; 0.03) | -121
Chang, 2006^73^ Entecavir (Baraclude, Bristol-Myers Squibb), 0.5 mg/day, 52 weeks | Lamivudine (Epivir-HBV, GlaxoSmithKline), 100 mg/day, 52 weeks | Discontinuation due to adverse event | 52/52 | 1/354 9/355 | 0/3 | 0.11 (0.01; 0.87) | -0.02 (-0.04; -0.01) | -44
Chang, 2006^73^ Entecavir (Baraclude, Bristol-Myers Squibb), 0.5 mg/day, 52 weeks | Lamivudine (Epivir-HBV, GlaxoSmithKline), 100 mg/day, 52 weeks | ALT >2 × baseline and >5× ULN | 52/52 | 37/354 59/355 | 10/17 | 0.63 (0.43; 0.92) | -0.06 (-0.11; -0.01) | -16
Chang, 2006^73^ Entecavir (Baraclude, Bristol-Myers Squibb), 0.5 mg/day, 52 weeks | Lamivudine (Epivir-HBV, GlaxoSmithKline), 100 mg/day, 52 weeks | ALT > 2 × reference value and >5× ULN | 76/76 | 3/354 16/355 | 1/5 | 0.19 (0.06; 0.64) | -0.04 (-0.06; -0.01) | -27
Chang, 2006^73^ Entecavir (Baraclude, Bristol-Myers Squibb), 0.5 mg/day, 52 weeks | Lamivudine (Epivir-HBV, GlaxoSmithKline), 100 mg/day, 52 weeks | Histological improvement- improvement by at least 2 points in the Knodell necroinflammatory score, with no worsening in the Knodell fibrosis score | 52/52 | 226/354 195/355 | 64/55 | 1.16 (1.03; 1.31) | 0.09 (0.02; 0.16) | 11
Chang, 2006^73^ Entecavir (Baraclude, Bristol-Myers Squibb), 0.5 mg/day, 52 weeks | Lamivudine (Epivir-HBV, GlaxoSmithKline), 100 mg/day, 52 weeks | No improvement in Knodell necroinflammatory score | 52/52 | 66/354 74/355 | 19/21 | 0.89 (0.66; 1.20) | -0.02 (-0.08; 0.04) | -45
Chang, 2006^73^ Entecavir (Baraclude, Bristol-Myers Squibb), 0.5 mg/day, 52 weeks | Lamivudine (Epivir-HBV, GlaxoSmithKline), 100 mg/day, 52 weeks | Improved Ishak fibrosis scores | 52/52 | 138/354 124/355 | 39/35 | 1.12 (0.92; 1.35) | 0.04 (-0.03; 0.11) | 25
Chang, 2006^73^ Entecavir (Baraclude, Bristol-Myers Squibb), 0.5 mg/day, 52 weeks | Lamivudine (Epivir-HBV, GlaxoSmithKline), 100 mg/day, 52 weeks | Worsened Ishak fibrosis scores | 52/52 | 28/354 36/355 | 8/10 | 0.78 (0.49; 1.25) | -0.02 (-0.06; 0.02) | -45
Chang, 2006^73^ Entecavir (Baraclude, Bristol-Myers Squibb), 0.5 mg/day, 52 weeks | Lamivudine (Epivir-HBV, GlaxoSmithKline), 100 mg/day, 52 weeks | HBV DNA <300 copies/ml by PCR assay | 52/52 | 236/354 129/355 | 67/36 | 1.83 (1.57; 2.14) | 0.30 (0.23; 0.37) | 3
Chang, 2006^73^ Entecavir (Baraclude, Bristol-Myers Squibb), 0.5 mg/day, 52 weeks | Lamivudine (Epivir-HBV, GlaxoSmithKline), 100 mg/day, 52 weeks | HBV DNA <0.7 MEq/ml by branched-chain DNA assay | 52/52 | 322/354 232/355 | 91/65 | 1.39 (1.28; 1.51) | 0.26 (0.20; 0.31) | 4
Chang, 2006^73^ Entecavir (Baraclude, Bristol-Myers Squibb), 0.5 mg/day, 52 weeks | Lamivudine (Epivir-HBV, GlaxoSmithKline), 100 mg/day, 52 weeks | Loss of HBeAg | 52/52 | 78/354 70/355 | 22/20 | 1.12 (0.84; 1.49) | 0.02 (-0.04; 0.08) | 43
Chang, 2006^73^ Entecavir (Baraclude, Bristol-Myers Squibb), 0.5 mg/day, 52 weeks | Lamivudine (Epivir-HBV, GlaxoSmithKline), 100 mg/day, 52 weeks | HBeAg seroconversion | 52/52 | 74/354 64/355 | 21/18 | 1.16 (0.86; 1.57) | 0.03 (-0.03; 0.09) | 35
Chang, 2006^73^ Entecavir (Baraclude, Bristol-Myers Squibb), 0.5 mg/day, 52 weeks | Lamivudine (Epivir-HBV, GlaxoSmithKline), 100 mg/day, 52 weeks | HBsAg loss | 52/52 | 6/354 4/355 | 2/1 | 1.50 (0.43; 5.28) | 0.01 (-0.01; 0.02) | 176
Chang, 2006^73^ Entecavir (Baraclude, Bristol-Myers Squibb), 0.5 mg/day, 52 weeks | Lamivudine (Epivir-HBV, GlaxoSmithKline), 100 mg/day, 52 weeks | HBV DNA level, ≥0.7 MEq per milliliter | 52/52 | 19/354 94/355 | 5/26 | 0.20 (0.13; 0.32) | -0.21 (-0.26; -0.16) | -5
Chang, 2006^73^ Entecavir (Baraclude, Bristol-Myers Squibb), 0.5 mg/day, 52 weeks | Lamivudine (Epivir-HBV, GlaxoSmithKline), 100 mg/day, 52 weeks | HBV DNA <0.7 MEq /ml and HBeAg loss | 52/52 | 74/354 67/355 | 21/19 | 1.11 (0.82; 1.49) | 0.02 (-0.04; 0.08) | 49
Chang, 2006^73^ Entecavir (Baraclude, Bristol-Myers Squibb), 0.5 mg/day, 52 weeks | Lamivudine (Epivir-HBV, GlaxoSmithKline), 100 mg/day, 52 weeks | HBV DNA level of < 0.7 MEq /ml, without HBeAg loss | 52/52 | 247/354 165/355 | 70/46 | 1.50 (1.32; 1.71) | 0.23 (0.16; 0.30) | 4
Chang, 2006^73^ Entecavir (Baraclude, Bristol-Myers Squibb), 0.5 mg/day, 52 weeks | Lamivudine (Epivir-HBV, GlaxoSmithKline), 100 mg/day, 52 weeks | HBV DNA < 0.7 MEq /ml and HBeAg loss | 76/76 | 61/354 49/355 | 17/14 | 1.25 (0.88; 1.76) | 0.03 (-0.02; 0.09) | 29
Chang, 2006^73^ Entecavir (Baraclude, Bristol-Myers Squibb), 0.5 mg/day, 52 weeks | Lamivudine (Epivir-HBV, GlaxoSmithKline), 100 mg/day, 52 weeks | Undetectable HBV DNA by PCR | 76/76 | 25/354 20/355 | 7/6 | 1.25 (0.71; 2.21) | 0.01 (-0.02; 0.05) | 70
Chang, 2006^73^ Entecavir (Baraclude, Bristol-Myers Squibb), 0.5 mg/day, 52 weeks | Lamivudine (Epivir-HBV, GlaxoSmithKline), 100 mg/day, 52 weeks | Virological rebound confirmed increase in the HBV DNA level by at least 1 log [on a base-10 scale] copy/ml from the nadir value | 76/76 | 6/354 63/355 | 2/18 | 0.10 (0.04; 0.22) | -0.16 (-0.20; -0.12) | -6
Chang, 2006^73^ Entecavir (Baraclude, Bristol-Myers Squibb), 0.5 mg/day, 52 weeks | Lamivudine (Epivir-HBV, GlaxoSmithKline), 100 mg/day, 52 weeks | ALT normalization (≤1.0 × ULN) | 52/52 | 253/325 222/313 | 78/71 | 1.10 (1.00; 1.20) | 0.07 (0.00; 0.14) | 14
Chang, 2006^73^ Entecavir (Baraclude, Bristol-Myers Squibb), 0.5 mg/day, 52 weeks | Lamivudine (Epivir-HBV, GlaxoSmithKline), 100 mg/day, 52 weeks | ALT >2 × baseline and >10× ULN | 52/52 | 3/325 5/313 | 1/2 | 0.58 (0.14; 2.40) | -0.01 (-0.02; 0.01) | -148
Chang, 2006^73^ Entecavir (Baraclude, Bristol-Myers Squibb), 0.5 mg/day, 52 weeks | Lamivudine (Epivir-HBV, GlaxoSmithKline), 100 mg/day, 52 weeks | ALT >2 × baseline and >10× ULN | 76/76 | 23/325 29/313 | 7/9 | 0.76 (0.45; 1.29) | -0.02 (-0.06; 0.02) | -46
Chang, 2006^73^ Entecavir (Baraclude, Bristol-Myers Squibb), 0.5 mg/day, 52 weeks | Lamivudine (Epivir-HBV, GlaxoSmithKline), 100 mg/day, 52 weeks | Death | 52/52 | 2/325 0/313 | 1/0 | 4.82 (0.23; 99.92) | 0.01 (0.00; 0.02) | 163
Chang, 2006^73^ Entecavir (Baraclude, Bristol-Myers Squibb), 0.5 mg/day, 52 weeks | Lamivudine (Epivir-HBV, GlaxoSmithKline), 100 mg/day, 52 weeks | Any adverse event | 52/52 | 246/325 248/313 | 76/79 | 0.96 (0.88; 1.04) | -0.04 (-0.10; 0.03) | -28
Chang, 2006^73^ Entecavir (Baraclude, Bristol-Myers Squibb), 0.5 mg/day, 52 weeks | Lamivudine (Epivir-HBV, GlaxoSmithKline), 100 mg/day, 52 weeks | Serious adverse event | 52/52 | 21/325 24/313 | 6/8 | 0.84 (0.48; 1.48) | -0.01 (-0.05; 0.03) | -83
Chang, 2006^73^ Entecavir (Baraclude, Bristol-Myers Squibb), 0.5 mg/day, 52 weeks | Lamivudine (Epivir-HBV, GlaxoSmithKline), 100 mg/day, 52 weeks | Discontinuation due to adverse event | 52/52 | 6/325 9/313 | 2/3 | 0.64 (0.23; 1.78) | -0.01 (-0.03; 0.01) | -97
Chang, 2006^73^ Entecavir (Baraclude, Bristol-Myers Squibb), 0.5 mg/day, 52 weeks | Lamivudine (Epivir-HBV, GlaxoSmithKline), 100 mg/day, 52 weeks | ALT >2 × baseline and >5× ULN | 52/52 | 6/325 10/313 | 2/3 | 0.58 (0.21; 1.57) | -0.01 (-0.04; 0.01) | -74
Chang, 2006^73^ Entecavir (Baraclude, Bristol-Myers Squibb), 0.5 mg/day, 52 weeks | Lamivudine (Epivir-HBV, GlaxoSmithKline), 100 mg/day, 52 weeks | ALT >2 × baseline and >5 × ULN | 76/76 | 36/325 77/313 | 11/25 | 0.45 (0.31; 0.65) | -0.14 (-0.19; -0.08) | -7
Chang, 2006^73^ Entecavir (Baraclude, Bristol-Myers Squibb), 0.5 mg/day, 52 weeks | Lamivudine (Epivir-HBV, GlaxoSmithKline), 100 mg/day, 52 weeks | Histological improvement- improvement by at least 2 points in the Knodell necroinflammatory score, with no worsening in the Knodell fibrosis score | 52/52 | 208/325 174/313 | 64/56 | 1.15 (1.01; 1.31) | 0.08 (0.01; 0.16) | 12
Chang, 2006^73^ Entecavir (Baraclude, Bristol-Myers Squibb), 0.5 mg/day, 52 weeks | Lamivudine (Epivir-HBV, GlaxoSmithKline), 100 mg/day, 52 weeks | No improvement in Knodell necroinflammatory score | 52/52 | 57/325 76/313 | 18/24 | 0.72 (0.53; 0.98) | -0.07 (-0.13; 0.00) | -15
Chang, 2006^73^ Entecavir (Baraclude, Bristol-Myers Squibb), 0.5 mg/day, 52 weeks | Lamivudine (Epivir-HBV, GlaxoSmithKline), 100 mg/day, 52 weeks | HBV DNA <300 copies/ml by PCR assay | 52/52 | 293/325 225/313 | 90/72 | 1.25 (1.16; 1.36) | 0.18 (0.12; 0.24) | 5
Chang, 2006^73^ Entecavir (Baraclude, Bristol-Myers Squibb), 0.5 mg/day, 52 weeks | Lamivudine (Epivir-HBV, GlaxoSmithKline), 100 mg/day, 52 weeks | HBV DNA <0.7 MEq/ml by branched-chain DNA assay | 52/52 | 309/325 279/313 | 95/89 | 1.07 (1.02; 1.12) | 0.06 (0.02; 0.10) | 17
Virological rebound confirmed increase in the HBV DNA level by at least 1 log [on a base-10 scale] copy/ml from the nadir value | 52/52 | 5/325 25/313 | 2/8 | 0.19 (0.07; 0.50) | -0.06 (-0.10; -0.03) | -16
Schiff, 2003^47^ Lamivudine, 100 mg/daily, 52 weeks | Placebo, 52 weeks | Normal ALT | 52/52 | 51/119 8/56 | 43/14 | 3.00 (1.53; 5.89) | 0.29 (0.16; 0.41) | 3
Schiff, 2003^47^ Lamivudine, 100 mg/daily, 52 weeks | Placebo, 52 weeks | Discontinuation due to adverse effects | 52/52 | 3/119 5/56 | 3/9 | 0.28 (0.07; 1.14) | -0.06 (-0.14; 0.02) | -16
Schiff, 2003^47^ Lamivudine, 100 mg/daily, 52 weeks | Placebo, 52 weeks | Malaise/fatigue | 52/52 | 32/119 18/56 | 27/32 | 0.84 (0.52; 1.36) | -0.05 (-0.20; 0.09) | -19
Schiff, 2003^47^ Lamivudine, 100 mg/daily, 52 weeks | Placebo, 52 weeks | Fever | 52/52 | 9/119 0/56 | 8/0 | 9.03 (0.53; 152.37) | 0.08 (0.02; 0.13) | 13
Schiff, 2003^47^ Lamivudine, 100 mg/daily, 52 weeks | Placebo, 52 weeks | Headache | 52/52 | 18/119 13/56 | 15/23 | 0.65 (0.34; 1.23) | -0.08 (-0.21; 0.05) | -12
Schiff, 2003^47^ Lamivudine, 100 mg/daily, 52 weeks | Placebo, 52 weeks | Nausea/vomiting | 52/52 | 20/119 11/56 | 17/20 | 0.86 (0.44; 1.66) | -0.03 (-0.15; 0.10) | -35
Schiff, 2003^47^ Lamivudine, 100 mg/daily, 52 weeks | Placebo, 52 weeks | Hair loss/alopecia | 52/52 | 2/119 2/56 | 2/4 | 0.47 (0.07; 3.26) | -0.02 (-0.07; 0.03) | -53
Schiff, 2003^47^ Lamivudine, 100 mg/daily, 52 weeks | Placebo, 52 weeks | Muscle pain | 52/52 | 22/119 5/56 | 18/9 | 2.07 (0.83; 5.18) | 0.10 (-0.01; 0.20) | 10
Schiff, 2003^47^ Lamivudine, 100 mg/daily, 52 weeks | Placebo, 52 weeks | Viral respiratory infections | 52/52 | 3/119 0/56 | 3/0 | 3.33 (0.17; 63.30) | 0.03 (-0.01; 0.06) | 40
Schiff, 2003^47^ Lamivudine, 100 mg/daily, 52 weeks | Placebo, 52 weeks | Feeding problems | 52/52 | 2/119 2/56 | 2/4 | 0.47 (0.07; 3.26) | -0.02 (-0.07; 0.03) | -53
Schiff, 2003^47^ Lamivudine, 100 mg/daily, 52 weeks | Placebo, 52 weeks | Depression | 52/52 | 5/119 2/56 | 4/4 | 1.18 (0.24; 5.88) | 0.01 (-0.05; 0.07) | 159
Schiff, 2003^47^ Lamivudine, 100 mg/daily, 52 weeks | Placebo, 52 weeks | Decreased WBCs | 52/52 | 1/119 0/56 | 1/0 | 1.43 (0.06; 34.44) | 0.01 (-0.02; 0.04) | 119
Schiff, 2003^47^ Lamivudine, 100 mg/daily, 52 weeks | Placebo, 52 weeks | Rheumatism | 52/52 | 6/119 2/56 | 5/4 | 1.41 (0.29; 6.78) | 0.01 (-0.05; 0.08) | 68
Schiff, 2003^47^ Lamivudine, 100 mg/daily, 52 weeks | Placebo, 52 weeks | Diarrhea | 52/52 | 15/119 0/56 | 13/0 | 14.73 (0.90; 241.77) | 0.13 (0.06; 0.19) | 8
Schiff, 2003^47^ Lamivudine, 100 mg/daily, 52 weeks | Placebo, 52 weeks | Abnormal ALT/AST | 52/52 | 22/119 9/56 | 18/16 | 1.15 (0.57; 2.33) | 0.02 (-0.09; 0.14) | 41
Schiff, 2003^47^ Lamivudine, 100 mg/daily, 52 weeks | Placebo, 52 weeks | Pain | 52/52 | 1/119 4/56 | 1/7 | 0.12 (0.01; 1.03) | -0.06 (-0.13; 0.01) | -16
Schiff, 2003^47^ Lamivudine, 100 mg/daily, 52 weeks | Placebo, 52 weeks | Musculoskeletal pain | 52/52 | 1/119 2/56 | 1/4 | 0.24 (0.02; 2.54) | -0.03 (-0.08; 0.02) | -37
Schiff, 2003^47^ Lamivudine, 100 mg/daily, 52 weeks | Placebo, 52 weeks | Abnormal enzymes (amylase/CPK) | 52/52 | 19/119 4/56 | 16/7 | 2.24 (0.80; 6.26) | 0.09 (-0.01; 0.18) | 11
Schiff, 2003^47^ Lamivudine, 100 mg/daily, 52 weeks | Placebo, 52 weeks | ALT >2 at baseline and >500U/l | 52/52 | 9/119 4/56 | 8/7 | 1.06 (0.34; 3.29) | 0.00 (-0.08; 0.09) | 238
Schiff, 2003^47^ Lamivudine, 100 mg/daily, 52 weeks | Placebo, 52 weeks | ALT >2 at baseline and >500U/l | 68/68 | 3/119 2/56 | 3/4 | 0.71 (0.12; 4.11) | -0.01 (-0.07; 0.05) | -95
Schiff, 2003^47^ Lamivudine, 100 mg/daily, 52 weeks | Placebo, 52 weeks | Histological response: reduction in HAI score >2 | 52/52 | 62/119 14/56 | 52/25 | 2.08 (1.28; 3.39) | 0.27 (0.13; 0.42) | 4
Schiff, 2003^47^ Lamivudine, 100 mg/daily, 52 weeks | Placebo, 52 weeks | Worsening in histology: increase in HAI by >2 scores | 52/52 | 8/119 9/56 | 7/16 | 0.42 (0.17; 1.03) | -0.09 (-0.20; 0.01) | -11
Schiff, 2003^47^ Lamivudine, 100 mg/daily, 52 weeks | Placebo, 52 weeks | Improved necroinflammatory activity | 52/52 | 63/119 16/56 | 53/29 | 1.85 (1.18; 2.90) | 0.24 (0.10; 0.39) | 4
Schiff, 2003^47^ Lamivudine, 100 mg/daily, 52 weeks | Placebo, 52 weeks | Worsening of fibrosis | 52/52 | 4/119 3/56 | 3/5 | 0.63 (0.15; 2.71) | -0.02 (-0.09; 0.05) | -50
Schiff, 2003^47^ Lamivudine, 100 mg/daily, 52 weeks | Placebo, 52 weeks | HBeAg loss | 52/52 | 38/119 7/56 | 32/12 | 2.55 (1.22; 5.36) | 0.19 (0.07; 0.31) | 5
Schiff, 2003^47^ Lamivudine, 100 mg/daily, 52 weeks | Placebo, 52 weeks | HBeAg loss | 68/68 | 40/119 9/56 | 34/16 | 2.09 (1.09; 4.00) | 0.18 (0.05; 0.30) | 6
Schiff, 2003^47^ Lamivudine, 100 mg/daily, 52 weeks | Placebo, 52 weeks | HBeAg seroconversion | 52/52 | 19/119 7/56 | 16/12 | 1.28 (0.57; 2.86) | 0.03 (-0.07; 0.14) | 29
Schiff, 2003^47^ Lamivudine, 100 mg/daily, 52 weeks | Placebo, 52 weeks | HBeAg seroconversion | 68/68 | 21/119 7/56 | 18/12 | 1.41 (0.64; 3.12) | 0.05 (-0.06; 0.16) | 19
Schiff, 2003^47^ Lamivudine, 100 mg/daily, 52 weeks | Placebo, 52 weeks | HBV DNA response: <3pg/ml | 52/52 | 102/119 23/56 | 86/41 | 2.09 (1.51; 2.88) | 0.45 (0.30; 0.59) | 2
Schiff, 2003^47^ Lamivudine, 100 mg/daily, 52 weeks | Placebo, 52 weeks | Sustained HBV DNA response: no two consecutive detectable HBV DNA | 52/52 | 60/119 9/56 | 50/16 | 3.14 (1.68; 5.86) | 0.34 (0.21; 0.48) | 3
Schiff, 2003^47^ Lamivudine, 100 mg/daily, 52 weeks | Placebo, 52 weeks | HBV DNA undetectable by PCR (<750 genomes/ml) | 52/52 | 34/119 8/56 | 29/14 | 2.00 (0.99; 4.03) | 0.14 (0.02; 0.27) | 7
Schiff, 2003^47^ Lamivudine, 100 mg/daily, 52 weeks | Placebo, 52 weeks | HBsAg loss | 52/52 | 2/119 0/56 | 2/0 | 2.38 (0.12; 48.66) | 0.02 (-0.02; 0.05) | 60
Schiff, 2003^47^ Lamivudine, 100 mg/daily, 52 weeks | Placebo, 52 weeks | HBsAg loss | 68/68 | 3/119 0/56 | 3/0 | 3.33 (0.17; 63.30) | 0.03 (-0.01; 0.06) | 40
Detectable YMDD-variant virus | 52/52 | 52/119 0/56 | 44/0 | 49.88 (3.13; 793.61) | 0.44 (0.34; 0.53) | 2
Yao, 2000^108^ Lamivudine, 100 mg/day, 12 weeks | Placebo, 12 weeks | ALT normalization | 12/12 | 91/322 14/107 | 28/13 | 2.16 (1.29; 3.63) | 0.15 (0.07; 0.23) | 7
Yao, 2000^108^ lamivudine, 100 mg/day, 60 weeks | Lamivudine, 100 mg/day, 48 weeks | ALT normalization | 60/48 | 102/322 36/107 | 32/34 | 0.94 (0.69; 1.28) | -0.02 (-0.12; 0.08) | -51
Yao, 2000^108^ Lamivudine, 100 mg/day, 12 weeks | Placebo, 12 weeks | >1 treatment-related event | 12/12 | 58/322 13/107 | 18/12 | 1.48 (0.85; 2.60) | 0.06 (-0.02; 0.13) | 17
Yao, 2000^108^ Lamivudine, 100 mg/day, 12 weeks | Placebo, 12 weeks | Gastrointestinal events | 12/12 | 25/322 6/107 | 8/6 | 1.38 (0.58; 3.28) | 0.02 (-0.03; 0.07) | 46
Neurological events | 39794 | 18/322 4/107 | 6/4 | 1.50 (0.52; 4.32) | 0.02 (-0.03; 0.06) | 54
Yao, 2000^108^ Lamivudine, 100 mg/day, 60 weeks | Lamivudine, 100 mg/day, 48 weeks | >1 drug-related event | 60/48 | 86/322 23/107 | 27/21 | 1.24 (0.83; 1.86) | 0.05 (-0.04; 0.14) | 19
Yao, 2000^108^ Lamivudine, 100 mg/day, 60 weeks | Lamivudine, 100 mg/day, 48 weeks | Gastrointestinal events | 60/48 | 35/322 11/107 | 11/10 | 1.06 (0.56; 2.01) | 0.01 (-0.06; 0.07) | 170
Yao, 2000^108^ Lamivudine, 100 mg/day, 60 weeks | Lamivudine, 100 mg/day, 48 weeks | Neurological events | 60/48 | 21/322 9/107 | 7/8 | 0.78 (0.37; 1.64) | -0.02 (-0.08; 0.04) | -53
Yao, 2000^108^ Lamivudine, 100 mg/day, 60 weeks | Lamivudine, 100 mg/day, 48 weeks | Events of the hepatobiliary tract and pancreas | 60/48 | 21/322 3/107 | 7/3 | 2.33 (0.71; 7.64) | 0.04 (0.00; 0.08) | 27
Non-site specific events | 60/48 | 20/322 7/107 | 6/7 | 0.95 (0.41; 2.18) | 0.00 (-0.06; 0.05) | -302
Yao, 2000^108^ Lamivudine, 100 mg/day, 12 weeks | Placebo, 12 weeks | Undetectable serum HBV DNA <1.6pg/ml | 12/12 | 269/322 14/107 | 84/13 | 6.38 (3.91; 10.43) | 0.70 (0.63; 0.78) | 1
Yao, 2000^108^ Lamivudine, 100 mg/day, 60 weeks | Lamivudine, 100 mg/day, 48 weeks | Undetectable serum HBV DNA <1.6pg/ml | 60/48 | 207/322 77/107 | 64/72 | 0.89 (0.77; 1.03) | -0.08 (-0.18; 0.02) | -13
Yao, 2000^108^ Lamivudine, 100 mg/day, 60 weeks | Lamivudine, 100 mg/day, 48 weeks | Breakthrough in serum HBV DNA | 60/48 | 65/266 7/82 | 24/9 | 2.86 (1.37; 6.00) | 0.16 (0.08; 0.24) | 6
Yao, 2000^108^ Lamivudine, 100 mg/day, 60 weeks | Lamivudine, 100 mg/day, 48 weeks | Mixed wild-type HBV plus pure YMDD variant | 60/48 | 31/322 4/107 | 10/4 | 2.58 (0.93; 7.13) | 0.06 (0.01; 0.11) | 17
Pure YMDD variant | 60/48 | 12/322 1/107 | 4/1 | 3.99 (0.52; 30.31) | 0.03 (0.00; 0.06) | 36
Peters, 2004^43^ Lamivudine, 100 mg/day, 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | Normalization ALT | 48/48 | 1/19 9/19 | 5/47 | 0.11 (0.02; 0.79) | -0.42 (-0.67; -0.18) | -2
Peters, 2004^43^ Lamivudine, 100 mg/day, 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | Any adverse event | 48/48 | 19/19 18/19 | 100/95 | 1.05 (0.91; 1.22) | 0.05 (-0.08; 0.19) | 19
Peters, 2004^43^ Lamivudine, 100 mg/day, 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | Asthenia | 48/48 | 6/19 9/19 | 32/47 | 0.67 (0.30; 1.50) | -0.16 (-0.46; 0.15) | -6
Peters, 2004^43^ Lamivudine, 100 mg/day, 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | Headache | 48/48 | 5/19 5/19 | 26/26 | 1.00 (0.35; 2.90) | 0.00 (-0.28; 0.28)
Peters, 2004^43^ Lamivudine, 100 mg/day, 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | Pharyngitis | 48/48 | 6/19 5/19 | 32/26 | 1.20 (0.44; 3.27) | 0.05 (-0.24; 0.34) | 19
Peters, 2004^43^ Lamivudine, 100 mg/day, 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | Abdominal pain | 48/48 | 5/19 4/19 | 26/21 | 1.25 (0.40; 3.95) | 0.05 (-0.22; 0.32) | 19
Peters, 2004^43^ Lamivudine, 100 mg/day, 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | Insomnia | 48/48 | 2/19 4/19 | 11/21 | 0.50 (0.10; 2.41) | -0.11 (-0.33; 0.12) | -9
Peters, 2004^43^ Lamivudine, 100 mg/day, 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | Rash | 48/48 | 4/19 4/19 | 21/21 | 1.00 (0.29; 3.43) | 0.00 (-0.26; 0.26)
Peters, 2004^43^ Lamivudine, 100 mg/day, 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | Fever | 48/48 | 1/19 3/19 | 5/16 | 0.33 (0.04; 2.93) | -0.11 (-0.30; 0.09) | -9
Peters, 2004^43^ Lamivudine, 100 mg/day, 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | Sinusitis | 48/48 | 5/19 3/19 | 26/16 | 1.67 (0.46; 6.01) | 0.11 (-0.15; 0.36) | 9
Peters, 2004^43^ Lamivudine, 100 mg/day, 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | Arthralgia | 48/48 | 3/19 2/19 | 16/11 | 1.50 (0.28; 7.99) | 0.05 (-0.16; 0.27) | 19
Peters, 2004^43^ Lamivudine, 100 mg/day, 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | Back pain | 48/48 | 3/19 2/19 | 16/11 | 1.50 (0.28; 7.99) | 0.05 (-0.16; 0.27) | 19
Peters, 2004^43^ Lamivudine, 100 mg/day, 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | Increased cough | 48/48 | 3/19 2/19 | 16/11 | 1.50 (0.28; 7.99) | 0.05 (-0.16; 0.27) | 19
Peters, 2004^43^ Lamivudine, 100 mg/day, 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | Nausea | 48/48 | 1/19 2/19 | 5/11 | 0.50 (0.05; 5.06) | -0.05 (-0.22; 0.12) | -19
Peters, 2004^43^ Lamivudine, 100 mg/day, 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | Pain | 48/48 | 4/19 2/19 | 21/11 | 2.00 (0.41; 9.65) | 0.11 (-0.12; 0.33) | 9
Peters, 2004^43^ Lamivudine, 100 mg/day, 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | Diarrhea | 48/48 | 6/19 1/19 | 32/5 | 6.00 (0.80; 45.20) | 0.26 (0.03; 0.50) | 4
Peters, 2004^43^ Lamivudine, 100 mg/day, 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | Gastroenteritis | 48/48 | 3/19 1/19 | 16/5 | 3.00 (0.34; 26.33) | 0.11 (-0.09; 0.30) | 9
Peters, 2004^43^ Lamivudine, 100 mg/day, 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | Infection | 48/48 | 1/19 1/19 | 5/5 | 1.00 (0.07; 14.85) | 0.00 (-0.14; 0.14)
Peters, 2004^43^ Lamivudine, 100 mg/day, 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | Rhinitis | 48/48 | 5/19 1/19 | 26/5 | 5.00 (0.64; 38.87) | 0.21 (-0.01; 0.43) | 5
Peters, 2004^43^ Lamivudine, 100 mg/day, 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | Bacterial infection | 48/48 | 0/19 0/19 | | | 0.00 (-0.10; 0.10)
Peters, 2004^43^ Lamivudine, 100 mg/day, 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | ALT Grade 3 (>5–10 times the ULN) | 48/48 | 0/19 7/19 | 0/37 | 0.07 (0.00; 1.09) | -0.37 (-0.59; -0.15) | -3
Peters, 2004^43^ Lamivudine, 100 mg/day, 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | ALT Grade 4 >10 times the ULN) | 48/48 | 3/19 0/19 | 16/0 | 7.00 (0.39; 126.92) | 0.16 (-0.02; 0.34) | 6
Peters, 2004^43^ Lamivudine, 100 mg/day, 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | AST Grade3 (>5–10 times the ULN) | 48/48 | 1/19 1/19 | 5/5 | 1.00 (0.07; 14.85) | 0.00 (-0.14; 0.14)
Peters, 2004^43^ Lamivudine, 100 mg/day, 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | Grade4 (>10 times the ULN) | 48/48 | 2/19 0/19 | 11/0 | 5.00 (0.26; 97.70) | 0.11 (-0.06; 0.27) | 9
Peters, 2004^43^ Lamivudine, 100 mg/day, 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | Amylase Grade3 (>2–5 times the ULN) | 48/48 | 3/19 0/19 | 16/0 | 7.00 (0.39; 126.92) | 0.16 (-0.02; 0.34) | 6
Peters, 2004^43^ Lamivudine, 100 mg/day, 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | Grade4 (5 times the ULN) | 48/48 | 0/19 0/19 | | | 0.00 (-0.10; 0.10)
Peters, 2004^43^ Lamivudine, 100 mg/day, 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | Serum Glucose Grade3 (30–39 mg/dL; 251–500 mg/dL) | 48/48 | 3/19 2/19 | 16/11 | 1.50 (0.28; 7.99) | 0.05 (-0.16; 0.27) | 19
Peters, 2004^43^ Lamivudine, 100 mg/day, 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | Grade4 (>30 mg/dL; <500 mg/dL) | 48/48 | 0/19 0/19 | | | 0.00 (-0.10; 0.10)
Peters, 2004^43^ Lamivudine, 100 mg/day, 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | Urine Glucose Grade3 (3+) | 48/48 | 4/19 2/19 | 21/11 | 2.00 (0.41; 9.65) | 0.11 (-0.12; 0.33) | 9
Peters, 2004^43^ Lamivudine, 100 mg/day, 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | Grade4 (4+) | 48/48 | 0/19 0/19 | | | 0.00 (-0.10; 0.10)
Peters, 2004^43^ Lamivudine, 100 mg/day, 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | HBV DNA undetectable | 48/48 | 0/19 5/19 | 0/26 | 0.09 (0.01; 1.54) | -0.26 (-0.47; -0.06) | -4
Peters, 2004^43^ Lamivudine, 100 mg/day, 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | HBeAg | 48/48 | 0/19 3/19 | 0/16 | 0.14 (0.01; 2.59) | -0.16 (-0.34; 0.02) | -6
HbeAg seroconversion | 48/48 | 0/19 2/19 | 0/11 | 0.20 (0.01; 3.91) | -0.11 (-0.27; 0.06) | -9
Yuen, 2005^111^ Lamivudine, 100 mg/day, 48 weeks | Placebo, 48 weeks | Improvement of necroinflammation | 48/48 | 37/67 3/18 | 55/17 | 3.31 (1.15; 9.52) | 0.39 (0.18; 0.59) | 3
Ke, 2005^53^ Lamivudine, 100 mg/day, 48 weeks | Routine medication with vitamin C and inosine, 48 weeks | HBV DNA became negative in serum | 24/24 | 34/42 5/30 | 81/17 | 4.86 (2.15; 10.96) | 0.64 (0.46; 0.82) | 2
Ke, 2005^53^ Lamivudine, 100 mg/day, 48 weeks | Routine medication with vitamin C and inosine, 48 weeks | HBV DNA negative in peripheral blood mononuclear cells | 24/24 | 20/42 4/30 | 48/13 | 3.57 (1.36; 9.38) | 0.34 (0.15; 0.54) | 3
Ke, 2005^53^ Lamivudine, 100 mg/day, 48 weeks | Routine medication with vitamin C and inosine, 48 weeks | HBV DNA negative in serum | 48/48 | 38/42 7/30 | 90/23 | 3.88 (2.01; 7.47) | 0.67 (0.50; 0.85) | 1
HBV DNA negative in peripheral blood mononuclear cells | 48/48 | 25/42 5/30 | 60/17 | 3.57 (1.54; 8.26) | 0.43 (0.23; 0.63) | 2
Nevins, 1997^55^ Lamivudine, 300 mg/day, 24 weeks | Lamivudine, 25 mg/day, 24 weeks | ALT normalization in patients with abnormal ALT at baseline | 24/24 | 5/19 7/16 | 26/44 | 0.60 (0.24; 1.53) | -0.17 (-0.49; 0.14) | -6
Nevins, 1997^55^ Lamivudine, 300 mg/day, 24 weeks | Lamivudine, 100 mg/day, 24 weeks | ALT normalization in patients with abnormal ALT at baseline | 24/24 | 5/19 5/16 | 26/31 | 0.84 (0.30; 2.40) | -0.05 (-0.35; 0.25) | -20
Nevins, 1997^55^ Lamivudine, 300 mg/day, 24 weeks | Lamivudine, 25 mg/day, 24 weeks | ALT normalization in patients with abnormal ALT at baseline | 24/24 | 5/16 7/16 | 31/44 | 0.71 (0.29; 1.78) | -0.13 (-0.46; 0.21) | -8
Nevins, 1997^55^ Lamivudine, 300 mg/day, 24 weeks | Lamivudine, 25 mg/day, 24 weeks | Twofold increase of ALT | 24/24 | 5/19 2/16 | 26/12 | 2.11 (0.47; 9.42) | 0.14 (-0.12; 0.39) | 7
Lamivudine, 100 mg/day, 24 weeks | Twofold increase of ALT | 24/24 | 5/19 4/16 | 26/25 | 1.05 (0.34; 3.27) | 0.01 (-0.28; 0.30) | 76
Nevins, 1997^55^ Lamivudine, 100 mg/day, 24 weeks | Lamivudine, 25 mg/day, 24 weeks | Twofold increase of ALT | 24/24 | 4/16 2/16 | 25/12 | 2.00 (0.42; 9.42) | 0.13 (-0.14; 0.39) | 8
Nevins, 1997^55^ Lamivudine, 300 mg/day, 24 weeks | Lamivudine, 25 mg/day, 24 weeks | Any adverse event | 24/24 | 5/19 5/16 | 26/31 | 0.84 (0.30; 2.40) | -0.05 (-0.35; 0.25) | -20
Lamivudine, 100 mg/day, 24 weeks | Any adverse event | 24/24 | 5/19 4/16 | 26/25 | 1.05 (0.34; 3.27) | 0.01 (-0.28; 0.30) | 76
Nevins, 1997^55^ Lamivudine, 100 mg/day, 24 weeks | Lamivudine, 25 mg/day, 24 weeks | Any adverse event | 24/24 | 4/16 5/16 | 25/31 | 0.80 (0.26; 2.45) | -0.06 (-0.37; 0.25) | -16
Nevins, 1997^55^ Lamivudine, 300 mg/day, 24 weeks | Lamivudine, 25 mg/day, 24 weeks | Nausea and vomiting | 24/24 | 2/19 2/16 | 11/12 | 0.84 (0.13; 5.32) | -0.02 (-0.23; 0.19) | -51
Nevins, 1997^55^ Lamivudine, 300 mg/day, 24 weeks | Lamivudine, 25 mg/day, 24 weeks | Fatigue | 24/24 | 2/19 0/16 | 11/0 | 4.25 (0.22; 82.57) | 0.11 (-0.06; 0.27) | 9
Nevins, 1997^55^ Lamivudine, 300 mg/day, 24 weeks | Lamivudine, 25 mg/day, 24 weeks | Abdominal discomfort and pain | 24/24 | 1/19 1/16 | 5/6 | 0.84 (0.06; 12.42) | -0.01 (-0.17; 0.15) | -101
Nevins, 1997^55^ Lamivudine, 300 mg/day, 24 weeks | Lamivudine, 25 mg/day, 24 weeks | Skin rashes | 24/24 | 0/19 1/16 | 0/6 | 0.28 (0.01; 6.51) | -0.06 (-0.21; 0.09) | -16
Nevins, 1997^55^ Lamivudine, 300 mg/day, 24 weeks | Lamivudine, 25 mg/day, 24 weeks | Diarrhea | 24/24 | 0/19 1/16 | 0/6 | 0.28 (0.01; 6.51) | -0.06 (-0.21; 0.09) | -16
Nevins, 1997^55^ Lamivudine, 300 mg/day, 24 weeks | Lamivudine, 25 mg/day, 24 weeks | Dizziness | 24/24 | 1/19 0/16 | 5/0 | 2.55 (0.11; 58.60) | 0.05 (-0.09; 0.19) | 19
Nevins, 1997^55^ Lamivudine, 300 mg/day, 24 weeks | Lamivudine, 25 mg/day, 24 weeks | Hypoglycemia | 24/24 | 1/19 0/16 | 5/0 | 2.55 (0.11; 58.60) | 0.05 (-0.09; 0.19) | 19
Nevins, 1997^55^ Lamivudine, 300 mg/day, 24 weeks | Lamivudine, 25 mg/day, 24 weeks | Headache | 24/24 | 0/19 0/16 | | | 0.00 (-0.11; 0.11)
Nevins, 1997^55^ Lamivudine, 300 mg/day, 24 weeks | Lamivudine, 25 mg/day, 24 weeks | Dyspepsia | 24/24 | 0/19 0/16 | | | 0.00 (-0.11; 0.11)
Nevins, 1997^55^ Lamivudine, 300 mg/day, 24 weeks | Lamivudine, 25 mg/day, 24 weeks | Vertigo | 24/24 | 0/19 0/16 | | | 0.00 (-0.11; 0.11)
Nevins, 1997^55^ Lamivudine, 300 mg/day, 24 weeks | Lamivudine, 25 mg/day, 24 weeks | Constipation | 24/24 | 0/19 0/16 | | | 0.00 (-0.11; 0.11)
Nevins, 1997^55^ Lamivudine, 300 mg/day, 24 weeks | Lamivudine, 25 mg/day, 24 weeks | Acne and folliculitis | 24/24 | 0/19 0/16 | | | 0.00 (-0.11; 0.11)
Nevins, 1997^55^ Lamivudine, 300 mg/day, 24 weeks | Lamivudine, 25 mg/day, 24 weeks | Eczema | 24/24 | 0/19 0/16 | | | 0.00 (-0.11; 0.11)
Nevins, 1997^55^ Lamivudine, 300 mg/day, 24 weeks | Lamivudine, 25 mg/day, 24 weeks | Muscle pain | 24/24 | 0/19 1/16 | 0/6 | 0.28 (0.01; 6.51) | -0.06 (-0.21; 0.09) | -16
Nevins, 1997^55^ Lamivudine, 300 mg/day, 24 weeks | Lamivudine, 25 mg/day, 24 weeks | Pigmentary skin disorders | 24/24 | 0/19 1/16 | 0/6 | 0.28 (0.01; 6.51) | -0.06 (-0.21; 0.09) | -16
Nevins, 1997^55^ Lamivudine, 300 mg/day, 24 weeks | Lamivudine, 25 mg/day, 24 weeks | Amylase >2× upper limit of normal | 24/24 | 0/19 1/16 | 0/6 | 0.28 (0.01; 6.51) | -0.06 (-0.21; 0.09) | -16
Nevins, 1997^55^ Lamivudine, 300 mg/day, 24 weeks | CPK >5× upper limit of normal | 24/24 | 2/19 0/16 | 11/0 | 4.25 (0.22; 82.57) | 0.11 (-0.06; 0.27) | 9
Nevins, 1997^55^ Lamivudine, 300 mg/day, 24 weeks | Lamivudine, 100 mg/day, 24 weeks | Nausea and vomiting | 24/24 | 2/19 0/16 | 11/0 | 4.25 (0.22; 82.57) | 0.11 (-0.06; 0.27) | 9
Nevins, 1997^55^ Lamivudine, 300 mg/day, 24 weeks | Lamivudine, 100 mg/day, 24 weeks | Fatigue | 24/24 | 2/19 1/16 | 11/6 | 1.68 (0.17; 16.91) | 0.04 (-0.14; 0.22) | 23
Nevins, 1997^55^ Lamivudine, 300 mg/day, 24 weeks | Lamivudine, 100 mg/day, 24 weeks | Abdominal discomfort and pain | 24/24 | 1/19 0/16 | 5/0 | 2.55 (0.11; 58.60) | 0.05 (-0.09; 0.19) | 19
Nevins, 1997^55^ Lamivudine, 300 mg/day, 24 weeks | Lamivudine, 100 mg/day, 24 weeks | Skin rashes | 24/24 | 0/19 1/16 | 0/6 | 0.28 (0.01; 6.51) | -0.06 (-0.21; 0.09) | -16
Nevins, 1997^55^ Lamivudine, 300 mg/day, 24 weeks | Lamivudine, 100 mg/day, 24 weeks | Diarrhea | 24/24 | 0/19 1/16 | 0/6 | 0.28 (0.01; 6.51) | -0.06 (-0.21; 0.09) | -16
Nevins, 1997^55^ Lamivudine, 300 mg/day, 24 weeks | Lamivudine, 100 mg/day, 24 weeks | Dizziness | 24/24 | 1/19 0/16 | 5/0 | 2.55 (0.11; 58.60) | 0.05 (-0.09; 0.19) | 19
Nevins, 1997^55^ Lamivudine, 300 mg/day, 24 weeks | Lamivudine, 100 mg/day, 24 weeks | Hypoglycemia | 24/24 | 1/19 0/16 | 5/0 | 2.55 (0.11; 58.60) | 0.05 (-0.09; 0.19) | 19
Nevins, 1997^55^ Lamivudine, 300 mg/day, 24 weeks | Lamivudine, 100 mg/day, 24 weeks | Headache | 24/24 | 0/19 1/16 | 0/6 | 0.28 (0.01; 6.51) | -0.06 (-0.21; 0.09) | -16
Nevins, 1997^55^ Lamivudine, 300 mg/day, 24 weeks | Lamivudine, 100 mg/day, 24 weeks | Dyspepsia | 24/24 | 0/19 1/16 | 0/6 | 0.28 (0.01; 6.51) | -0.06 (-0.21; 0.09) | -16
Nevins, 1997^55^ Lamivudine, 300 mg/day, 24 weeks | Lamivudine, 100 mg/day, 24 weeks | Vertigo | 24/24 | 0/19 1/16 | 0/6 | 0.28 (0.01; 6.51) | -0.06 (-0.21; 0.09) | -16
Nevins, 1997^55^ Lamivudine, 300 mg/day, 24 weeks | Lamivudine, 100 mg/day, 24 weeks | Constipation | 24/24 | 0/19 1/16 | 0/6 | 0.28 (0.01; 6.51) | -0.06 (-0.21; 0.09) | -16
Nevins, 1997^55^ Lamivudine, 300 mg/day, 24 weeks | Lamivudine, 100 mg/day, 24 weeks | Acne and folliculitis | 24/24 | 0/19 1/16 | 0/6 | 0.28 (0.01; 6.51) | -0.06 (-0.21; 0.09) | -16
Nevins, 1997^55^ Lamivudine, 300 mg/day, 24 weeks | Lamivudine, 100 mg/day, 24 weeks | Eczema | 24/24 | 0/19 1/16 | 0/6 | 0.28 (0.01; 6.51) | -0.06 (-0.21; 0.09) | -16
Nevins, 1997^55^ Lamivudine, 300 mg/day, 24 weeks | Lamivudine, 100 mg/day, 24 weeks | Muscle pain | 24/24 | 0/19 0/16 | | | 0.00 (-0.11; 0.11)
Nevins, 1997^55^ Lamivudine, 300 mg/day, 24 weeks | Lamivudine, 100 mg/day, 24 weeks | Pigmentary skin disorders | 24/24 | 0/19 0/16 | | | 0.00 (-0.11; 0.11)
Nevins, 1997^55^ Lamivudine, 300 mg/day, 24 weeks | Lamivudine, 100 mg/day, 24 weeks | Amylase >cc | 24/24 | 0/19 0/16 | | | 0.00 (-0.11; 0.11)
CPK >5× upper limit of normal | 24/24 | 2/19 0/16 | 11/0 | 4.25 (0.22; 82.57) | 0.11 (-0.06; 0.27) | 9
Nevens, 1997^55^ Lamivudine, 100 mg/day, 24 weeks | Lamivudine, 25 mg/day, 24 weeks | Nausea and vomiting | 24/24 | 0/16 2/16 | 0/12 | 0.20 (0.01; 3.86) | -0.13 (-0.31; 0.06) | -8
Nevens, 1997^55^ Lamivudine, 100 mg/day, 24 weeks | Lamivudine, 25 mg/day, 24 weeks | Fatigue | 24/24 | 1/16 0/16 | 6/0 | 3.00 (0.13; 68.57) | 0.06 (-0.09; 0.22) | 16
Nevens, 1997^55^ Lamivudine, 100 mg/day, 24 weeks | Lamivudine, 25 mg/day, 24 weeks | Abdominal discomfort and pain | 24/24 | 0/16 1/16 | 0/6 | 0.33 (0.01; 7.62) | -0.06 (-0.22; 0.09) | -16
Nevens, 1997^55^ Lamivudine, 100 mg/day, 24 weeks | Lamivudine, 25 mg/day, 24 weeks | Skin rashes | 24/24 | 1/16 1/16 | 6/6 | 1.00 (0.07; 14.64) | 0.00 (-0.17; 0.17)
Nevens, 1997^55^ Lamivudine, 100 mg/day, 24 weeks | Lamivudine, 25 mg/day, 24 weeks | Diarrhea | 24/24 | 1/16 1/16 | 6/6 | 1.00 (0.07; 14.64) | 0.00 (-0.17; 0.17)
Nevens, 1997^55^ Lamivudine, 100 mg/day, 24 weeks | Lamivudine, 25 mg/day, 24 weeks | Dizziness | 24/24 | 0/16 0/16 | | | 0.00 (-0.11; 0.11)
Nevens, 1997^55^ Lamivudine, 100 mg/day, 24 weeks | Lamivudine, 25 mg/day, 24 weeks | Hypoglycemia | 24/24 | 0/16 0/16 | | | 0.00 (-0.11; 0.11)
Nevens, 1997^55^ Lamivudine, 100 mg/day, 24 weeks | Lamivudine, 25 mg/day, 24 weeks | Headache | 24/24 | 1/16 0/16 | 6/0 | 3.00 (0.13; 68.57) | 0.06 (-0.09; 0.22) | 16
Nevens, 1997^55^ Lamivudine, 100 mg/day, 24 weeks | Lamivudine, 25 mg/day, 24 weeks | Dyspepsia | 24/24 | 1/16 0/16 | 6/0 | 3.00 (0.13; 68.57) | 0.06 (-0.09; 0.22) | 16
Nevens, 1997^55^ Lamivudine, 100 mg/day, 24 weeks | Lamivudine, 25 mg/day, 24 weeks | Vertigo | 24/24 | 1/16 0/16 | 6/0 | 3.00 (0.13; 68.57) | 0.06 (-0.09; 0.22) | 16
Nevens, 1997^55^ Lamivudine, 100 mg/day, 24 weeks | Lamivudine, 25 mg/day, 24 weeks | Constipation | 24/24 | 1/16 0/16 | 6/0 | 3.00 (0.13; 68.57) | 0.06 (-0.09; 0.22) | 16
Nevens, 1997^55^ Lamivudine, 100 mg/day, 24 weeks | Lamivudine, 25 mg/day, 24 weeks | Acne and folliculitis | 24/24 | 1/16 0/16 | 6/0 | 3.00 (0.13; 68.57) | 0.06 (-0.09; 0.22) | 16
Nevens, 1997^55^ Lamivudine, 100 mg/day, 24 weeks | Lamivudine, 25 mg/day, 24 weeks | Eczema | 24/24 | 1/16 0/16 | 6/0 | 3.00 (0.13; 68.57) | 0.06 (-0.09; 0.22) | 16
Nevens, 1997^55^ Lamivudine, 100 mg/day, 24 weeks | Lamivudine, 25 mg/day, 24 weeks | Muscle pain | 24/24 | 0/16 1/16 | 0/6 | 0.33 (0.01; 7.62) | -0.06 (-0.22; 0.09) | -16
Nevens, 1997^55^ Lamivudine, 100 mg/day, 24 weeks | Lamivudine, 25 mg/day, 24 weeks | Pigmentary skin disorders | 24/24 | 0/16 1/16 | 0/6 | 0.33 (0.01; 7.62) | -0.06 (-0.22; 0.09) | -16
Nevens, 1997^55^ Lamivudine, 100 mg/day, 24 weeks | Lamivudine, 25 mg/day, 24 weeks | Amylase >2× upper limit of normal | 24/24 | 0/16 1/16 | 0/6 | 0.33 (0.01; 7.62) | -0.06 (-0.22; 0.09) | -16
CPK >5× upper limit of normal | 24/24 | 0/16 0/16 | | | 0.00 (-0.11; 0.11)
Lai, 1998^50^ Lamivudine, 25 mg/day, 48 weeks | Lamivudine, 100 mg/day, 48 weeks | ALT normalization | 48/48 | 64/142 68/143 | 45/48 | 0.95 (0.74; 1.22) | -0.02 (-0.14; 0.09) | -40
Placebo, 48 weeks | ALT normalization | 48/48 | 64/142 12/73 | 45/16 | 2.74 (1.58; 4.74) | 0.29 (0.17; 0.40) | 3
Lai, 1998^50^ Lamivudine, 100 mg/day, 48 weeks | Placebo, 48 weeks | ALT normalization | 48/48 | 68/143 12/73 | 48/16 | 2.89 (1.68; 4.99) | 0.31 (0.19; 0.43) | 3
Lai, 1998^50^ Lamivudine, 25 mg/day, 48 weeks | Lamivudine, 100 mg/day, 48 weeks | >1 adverse event | 48/48 | 110/142 114/143 | 77/80 | 0.97 (0.86; 1.10) | -0.02 (-0.12; 0.07) | -44
Placebo, 48 weeks | >1 adverse event | 48/48 | 110/142 56/73 | 77/77 | 1.01 (0.87; 1.18) | 0.01 (-0.11; 0.13) | 133
Lai, 1998^50^ Lamivudine, 100 mg/day, 48 weeks | Placebo, 48 weeks | >1 adverse event | 48/48 | 114/143 56/73 | 80/77 | 1.04 (0.89; 1.21) | 0.03 (-0.09; 0.15) | 33
Lai, 1998^50^ Lamivudine, 25 mg/day, 48 weeks | Lamivudine, 100 mg/day, 48 weeks | Respiratory infections | 48/48 | 50/142 50/143 | 35/35 | 1.01 (0.73; 1.38) | 0.00 (-0.11; 0.11) | 406
Lai, 1998^50^ Lamivudine, 25 mg/day, 48 weeks | Lamivudine, 100 mg/day, 48 weeks | Headache | 48/48 | 23/142 21/143 | 16/15 | 1.10 (0.64; 1.90) | 0.02 (-0.07; 0.10) | 66
Lai, 1998^50^ Lamivudine, 25 mg/day, 48 weeks | Lamivudine, 100 mg/day, 48 weeks | Cough | 48/48 | 23/142 21/143 | 16/15 | 1.10 (0.64; 1.90) | 0.02 (-0.07; 0.10) | 66
Lai, 1998^50^ Lamivudine, 25 mg/day, 48 weeks | Lamivudine, 100 mg/day, 48 weeks | Abdominal discomfort or pain | 48/48 | 26/142 19/143 | 18/13 | 1.38 (0.80; 2.37) | 0.05 (-0.03; 0.13) | 20
Lai, 1998^50^ Lamivudine, 25 mg/day, 48 weeks | Lamivudine, 100 mg/day, 48 weeks | Diarrhea | 48/48 | 20/142 24/143 | 14/17 | 0.84 (0.49; 1.45) | -0.03 (-0.11; 0.06) | -37
Lai, 1998^50^ Lamivudine, 25 mg/day, 48 weeks | Lamivudine, 100 mg/day, 48 weeks | Malaise and fatigue | 48/48 | 17/142 19/143 | 12/13 | 0.90 (0.49; 1.66) | -0.01 (-0.09; 0.06) | -76
Lai, 1998^50^ Lamivudine, 25 mg/day, 48 weeks | Lamivudine, 100 mg/day, 48 weeks | Throat discomfort or pain | 48/48 | 18/142 23/143 | 13/16 | 0.79 (0.45; 1.40) | -0.03 (-0.12; 0.05) | -29
Lai, 1998^50^ Lamivudine, 25 mg/day, 48 weeks | Lamivudine, 100 mg/day, 48 weeks | Nasal signs and symptoms | 48/48 | 10/142 10/143 | 7/7 | 1.01 (0.43; 2.34) | 0.00 (-0.06; 0.06) | 2030
Lai, 1998^50^ Lamivudine, 25 mg/day, 48 weeks | Lamivudine, 100 mg/day, 48 weeks | Dizziness | 48/48 | 9/142 9/143 | 6/6 | 1.01 (0.41; 2.46) | 0.00 (-0.06; 0.06) | 2256
Lai, 1998^50^ Lamivudine, 25 mg/day, 48 weeks | Lamivudine, 100 mg/day, 48 weeks | Nausea and vomiting | 48/48 | 4/142 11/143 | 3/8 | 0.37 (0.12; 1.12) | -0.05 (-0.10; 0.00) | -21
Lai, 1998^50^ Lamivudine, 25 mg/day, 48 weeks | Lamivudine, 100 mg/day, 48 weeks | Fever | 48/48 | 9/142 9/143 | 6/6 | 1.01 (0.41; 2.46) | 0.00 (-0.06; 0.06) | 2256
Lai, 1998^50^ Lamivudine, 25 mg/day, 48 weeks | Lamivudine, 100 mg/day, 48 weeks | Chest symptoms | 48/48 | 3/142 4/143 | 2/3 | 0.76 (0.17; 3.31) | -0.01 (-0.04; 0.03) | -146
Lai, 1998^50^ Lamivudine, 25 mg/day, 48 weeks | Lamivudine, 100 mg/day, 48 weeks | Abnormal liver-function results | 48/48 | 6/142 3/143 | 4/2 | 2.01 (0.51; 7.90) | 0.02 (-0.02; 0.06) | 47
Lai, 1998^50^ Lamivudine, 25 mg/day, 48 weeks | Hair loss | 48/48 | 0/142 3/143 | 0/2 | 0.14 (0.01; 2.76) | -0.02 (-0.05; 0.01) | -48
Lai, 1998^50^ Lamivudine, 25 mg/day, 48 weeks | Placebo, 48 weeks | Respiratory infections | 48/48 | 50/142 21/73 | 35/29 | 1.22 (0.80; 1.87) | 0.06 (-0.07; 0.19) | 16
Lai, 1998^50^ Lamivudine, 25 mg/day, 48 weeks | Placebo, 48 weeks | Headache | 48/48 | 23/142 14/73 | 16/19 | 0.84 (0.46; 1.54) | -0.03 (-0.14; 0.08) | -34
Lai, 1998^50^ Lamivudine, 25 mg/day, 48 weeks | Placebo, 48 weeks | Cough | 48/48 | 23/142 12/73 | 16/16 | 0.99 (0.52; 1.87) | 0.00 (-0.11; 0.10) | -415
Lai, 1998^50^ Lamivudine, 25 mg/day, 48 weeks | Placebo, 48 weeks | Abdominal discomfort or pain | 48/48 | 26/142 9/73 | 18/12 | 1.49 (0.73; 3.00) | 0.06 (-0.04; 0.16) | 17
Lai, 1998^50^ Lamivudine, 25 mg/day, 48 weeks | Placebo, 48 weeks | Diarrhea | 48/48 | 20/142 7/73 | 14/10 | 1.47 (0.65; 3.31) | 0.04 (-0.04; 0.13) | 22
Lai, 1998^50^ Lamivudine, 25 mg/day, 48 weeks | Placebo, 48 weeks | Malaise and fatigue | 48/48 | 17/142 14/73 | 12/19 | 0.62 (0.33; 1.19) | -0.07 (-0.18; 0.03) | -14
Lai, 1998^50^ Lamivudine, 25 mg/day, 48 weeks | Placebo, 48 weeks | Throat discomfort or pain | 48/48 | 18/142 6/73 | 13/8 | 1.54 (0.64; 3.72) | 0.04 (-0.04; 0.13) | 22
Lai, 1998^50^ Lamivudine, 25 mg/day, 48 weeks | Placebo, 48 weeks | Nasal signs and symptoms | 48/48 | 10/142 6/73 | 7/8 | 0.86 (0.32; 2.26) | -0.01 (-0.09; 0.06) | -85
Lai, 1998^50^ Lamivudine, 25 mg/day, 48 weeks | Placebo, 48 weeks | Dizziness | 48/48 | 9/142 3/73 | 6/4 | 1.54 (0.43; 5.52) | 0.02 (-0.04; 0.08) | 45
Lai, 1998^50^ Lamivudine, 25 mg/day, 48 weeks | Placebo, 48 weeks | Nausea and vomiting | 48/48 | 4/142 1/73 | 3/1 | 2.06 (0.23; 18.07) | 0.01 (-0.02; 0.05) | 69
Lai, 1998^50^ Lamivudine, 25 mg/day, 48 weeks | Placebo, 48 weeks | Fever | 48/48 | 9/142 2/73 | 6/3 | 2.31 (0.51; 10.43) | 0.04 (-0.02; 0.09) | 28
Lai, 1998^50^ Lamivudine, 25 mg/day, 48 weeks | Placebo, 48 weeks | Chest symptoms | 48/48 | 3/142 5/73 | 2/7 | 0.31 (0.08; 1.25) | -0.05 (-0.11; 0.02) | -21
Lai, 1998^50^ Lamivudine, 25 mg/day, 48 weeks | Placebo, 48 weeks | Abnormal liver-function results | 48/48 | 6/142 6/73 | 4/8 | 0.51 (0.17; 1.54) | -0.04 (-0.11; 0.03) | -25
Hair loss | 48/48 | 0/142 4/73 | 0/5 | 0.06 (0.00; 1.05) | -0.05 (-0.11; 0.00) | -18
Lai, 1998^50^ Lamivudine, 100 mg/day, 48 weeks | Placebo, 48 weeks | Respiratory infections | 48/48 | 50/143 21/73 | 35/29 | 1.22 (0.79; 1.86) | 0.06 (-0.07; 0.19) | 16
Lai, 1998^50^ Lamivudine, 100 mg/day, 48 weeks | Placebo, 48 weeks | Headache | 48/48 | 21/143 14/73 | 15/19 | 0.77 (0.41; 1.42) | -0.04 (-0.15; 0.06) | -22
Lai, 1998^50^ Lamivudine, 100 mg/day, 48 weeks | Placebo, 48 weeks | Cough | 48/48 | 21/143 12/73 | 15/16 | 0.89 (0.47; 1.71) | -0.02 (-0.12; 0.09) | -57
Lai, 1998^50^ Lamivudine, 100 mg/day, 48 weeks | Placebo, 48 weeks | Abdominal discomfort or pain | 48/48 | 19/143 9/73 | 13/12 | 1.08 (0.51; 2.26) | 0.01 (-0.08; 0.10) | 104
Lai, 1998^50^ Lamivudine, 100 mg/day, 48 weeks | Placebo, 48 weeks | Diarrhea | 48/48 | 24/143 7/73 | 17/10 | 1.75 (0.79; 3.87) | 0.07 (-0.02; 0.16) | 14
Lai, 1998^50^ Lamivudine, 100 mg/day, 48 weeks | Placebo, 48 weeks | Malaise and fatigue | 48/48 | 19/143 14/73 | 13/19 | 0.69 (0.37; 1.30) | -0.06 (-0.16; 0.05) | -17
Lai, 1998^50^ Lamivudine, 100 mg/day, 48 weeks | Placebo, 48 weeks | Throat discomfort or pain | 48/48 | 23/143 6/73 | 16/8 | 1.96 (0.83; 4.59) | 0.08 (-0.01; 0.17) | 13
Lai, 1998^50^ Lamivudine, 100 mg/day, 48 weeks | Placebo, 48 weeks | Nasal signs and symptoms | 48/48 | 10/143 6/73 | 7/8 | 0.85 (0.32; 2.25) | -0.01 (-0.09; 0.06) | -82
Lai, 1998^50^ Lamivudine, 100 mg/day, 48 weeks | Placebo, 48 weeks | Dizziness | 48/48 | 9/143 3/73 | 6/4 | 1.53 (0.43; 5.49) | 0.02 (-0.04; 0.08) | 46
Lai, 1998^50^ Lamivudine, 100 mg/day, 48 weeks | Placebo, 48 weeks | Nausea and vomiting | 48/48 | 11/143 1/73 | 8/1 | 5.62 (0.74; 42.65) | 0.06 (0.01; 0.11) | 16
Lai, 1998^50^ Lamivudine, 100 mg/day, 48 weeks | Placebo, 48 weeks | Fever | 48/48 | 9/143 2/73 | 6/3 | 2.30 (0.51; 10.36) | 0.04 (-0.02; 0.09) | 28
Lai, 1998^50^ Lamivudine, 100 mg/day, 48 weeks | Placebo, 48 weeks | Chest symptoms | 48/48 | 4/143 5/73 | 3/7 | 0.41 (0.11; 1.48) | -0.04 (-0.10; 0.02) | -25
Lai, 1998^50^ Lamivudine, 100 mg/day, 48 weeks | Placebo, 48 weeks | Abnormal liver-function results | 48/48 | 3/143 6/73 | 2/8 | 0.26 (0.07; 0.99) | -0.06 (-0.13; 0.01) | -16
Hair loss | 48/48 | 3/143 4/73 | 2/5 | 0.38 (0.09; 1.67) | -0.03 (-0.09; 0.02) | -30
Lai, 1998^50^ Lamivudine, 25 mg/day, 48 weeks | Lamivudine, 100 mg/day, 48 weeks | Histological response was defined as a reduction of 2 or more points in the Knodell necroinflammatory score (components 1 through 3) | 48/48 | 70/142 80/143 | 49/56 | 0.88 (0.71; 1.10) | -0.07 (-0.18; 0.05) | -15
Lai, 1998^50^ Lamivudine, 25 mg/day, 48 weeks | Worsening of Knodell necroinflammatory score | 48/48 | 12/142 10/143 | 8/7 | 1.21 (0.54; 2.71) | 0.01 (-0.05; 0.08) | 69
Lai, 1998^50^ Lamivudine, 25 mg/day, 48 weeks | Placebo, 48 weeks | Histological response was defined as a reduction of 2 or more points in the Knodell necroinflammatory score (components 1 through 3) | 48/48 | 70/142 18/73 | 49/25 | 2.00 (1.29; 3.09) | 0.25 (0.12; 0.37) | 4
Worsening of Knodell necroinflammatory score | 48/48 | 12/142 19/73 | 8/26 | 0.32 (0.17; 0.63) | -0.18 (-0.29; -0.07) | -6
Lai, 1998^50^ Lamivudine, 100 mg/day, 48 weeks | Placebo, 48 weeks | Histological response was defined as a reduction of 2 or more points in the Knodell necroinflammatory score (components 1 through 3). | 48/48 | 80/143 18/73 | 56/25 | 2.27 (1.48; 3.48) | 0.31 (0.18; 0.44) | 3
Worsening of Knodell necroinflammatory score | 48/48 | 10/143 19/73 | 7/26 | 0.27 (0.13; 0.55) | -0.19 (-0.30; -0.08) | -5
Lai, 1998^50^ Lamivudine, 25 mg/day, 48 weeks | Lamivudine, 100 mg/day, 48 weeks | HBeAg seroconversion | 48/48 | 17/142 22/143 | 12/15 | 0.78 (0.43; 1.40) | -0.03 (-0.11; 0.05) | -29
Placebo, 48 weeks | HBeAg seroconversion | 48/48 | 17/142 3/73 | 12/4 | 2.91 (0.88; 9.62) | 0.08 (0.01; 0.15) | 13
Lai, 1998^50^ Lamivudine, 100 mg/day, 48 weeks | Placebo, 48 weeks | HBeAg seroconversion | 48/48 | 22/143 3/73 | 15/4 | 3.74 (1.16; 12.10) | 0.11 (0.04; 0.19) | 9
Lai, 1998^50^ Lamivudine, 25 mg/day, 48 weeks | Lamivudine, 100 mg/day, 48 weeks | Undetectable HBV DNA on at least one occasion | 48/48 | 104/142 129/143 | 73/90 | 0.81 (0.73; 0.91) | -0.17 (-0.26; -0.08) | -6
Placebo, 48 weeks | Undetectable HBV DNA on at least one occasion | 48/48 | 104/142 17/73 | 73/23 | 3.14 (2.05; 4.83) | 0.50 (0.38; 0.62) | 2
Lai, 1998^50^ lamivudine, 100 mg/day, 48 weeks | Placebo, 48 weeks | Undetectable HBV DNA on at least one occasion | 48/48 | 129/143 17/73 | 90/23 | 3.87 (2.55; 5.89) | 0.67 (0.56; 0.78) | 1
Honkoop, 1998^109^ Lamivudine, 300 mg/day, 24 weeks | Lamivudine, 25 mg/day, 24 weeks | Undetectable with PCR HBV DNA | 39794 | 15/19 7/16 | 79/44 | 1.80 (0.99; 3.30) | 0.35 (0.05; 0.66) | 3
Lamivudine, 100 mg/day, 24 weeks | Undetectable with PCR HBV DNA | 39794 | 15/19 14/16 | 79/88 | 0.90 (0.67; 1.21) | -0.09 (-0.33; 0.16) | -12
Honkoop, 1998^109^ Lamivudine, 100 mg/day, 24 weeks | Lamivudine, 25 mg/day, 24 weeks | Undetectable with PCR HBV DNA | 39794 | 14/16 7/16 | 88/44 | 2.00 (1.11; 3.59) | 0.44 (0.15; 0.73) | 2
Honkoop, 1998^109^ Lamivudine, 300 mg/day, 24 weeks | Lamivudine, 25 mg/day, 24 weeks | Undetectable with PCR HBV DNA | 24/24 | 13/19 6/16 | 68/38 | 1.82 (0.90; 3.68) | 0.31 (-0.01; 0.63) | 3
Lamivudine, 100 mg/day, 24 weeks | Undetectable with PCR HBV DNA | 24/24 | 13/19 12/16 | 68/75 | 0.91 (0.60; 1.38) | -0.07 (-0.36; 0.23) | -15
Honkoop, 1998^109^ Lamivudine, 100 mg/day, 24 weeks | Lamivudine, 25 mg/day, 24 weeks | Undetectable with PCR HBV DNA | 24/24 | 12/16 6/16 | 75/38 | 2.00 (1.00; 4.00) | 0.38 (0.06; 0.69) | 3
Tassopoulos, 1999^49^ Lamivudine, 100 mg/day after 6 months of previous LAM treatment, 52 weeks | Placebo, 26 weeks | HBV DNA <2.5 pg/mL and ALT normalization | 24/24 | 34/60 3/65 | 57/5 | 12.28 (3.98; 37.90) | 0.52 (0.39; 0.66) | 2
Tassopoulos, 1999^49^ Lamivudine, 100 mg/day after 6 months of previous LAM treatment, 52 weeks | Placebo, 26 weeks | Headache | 26/26 | 10/60 12/65 | 17/18 | 0.90 (0.42; 1.93) | -0.02 (-0.15; 0.12) | -56
Tassopoulos, 1999^49^ Lamivudine, 100 mg/day after 6 months of previous LAM treatment, 52 weeks | Placebo, 26 weeks | Malaise and fatigue | 26/26 | 8/60 8/65 | 13/12 | 1.08 (0.43; 2.70) | 0.01 (-0.11; 0.13) | 98
Tassopoulos, 1999^49^ Lamivudine, 100 mg/day after 6 months of previous LAM treatment, 52 weeks | Placebo, 26 weeks | Abdominal discomfort and pain | 26/26 | 4/60 8/65 | 7/12 | 0.54 (0.17; 1.71) | -0.06 (-0.16; 0.05) | -18
Tassopoulos, 1999^49^ Lamivudine, 100 mg/day after 6 months of previous LAM treatment, 52 weeks | Placebo, 26 weeks | Temperature regulation disturbance | 26/26 | 5/60 4/65 | 8/6 | 1.35 (0.38; 4.81) | 0.02 (-0.07; 0.11) | 46
Tassopoulos, 1999^49^ Lamivudine, 100 mg/day after 6 months of previous LAM treatment, 52 weeks | Placebo, 26 weeks | Cough | 26/26 | 4/60 3/65 | 7/5 | 1.44 (0.34; 6.19) | 0.02 (-0.06; 0.10) | 49
Tassopoulos, 1999^49^ Lamivudine, 100 mg/day after 6 months of previous LAM treatment, 52 weeks | Placebo, 26 weeks | Viral respiratory infections | 26/26 | 3/60 2/65 | 5/3 | 1.63 (0.28; 9.39) | 0.02 (-0.05; 0.09) | 52
Tassopoulos, 1999^49^ Lamivudine, 100 mg/day after 6 months of previous LAM treatment, 52 weeks | Placebo, 26 weeks | Gastrointestinal infections | 26/26 | 3/60 3/65 | 5/5 | 1.08 (0.23; 5.16) | 0.00 (-0.07; 0.08) | 260
Tassopoulos, 1999^49^ Lamivudine, 100 mg/day after 6 months of previous LAM treatment, 52 weeks | Placebo, 26 weeks | Musculoskeletal pain | 26/26 | 2/60 4/65 | 3/6 | 0.54 (0.10; 2.85) | -0.03 (-0.10; 0.05) | -35
Tassopoulos, 1999^49^ Lamivudine, 100 mg/day after 6 months of previous LAM treatment, 52 weeks | Placebo, 26 weeks | Nausea and vomiting | 26/26 | 5/60 1/65 | 8/2 | 5.42 (0.65; 45.04) | 0.07 (-0.01; 0.14) | 15
Tassopoulos, 1999^49^ Lamivudine, 100 mg/day after 6 months of previous LAM treatment, 52 weeks | Placebo, 26 weeks | Vertigo | 26/26 | 1/60 4/65 | 2/6 | 0.27 (0.03; 2.36) | -0.04 (-0.11; 0.02) | -22
Tassopoulos, 1999^49^ Lamivudine, 100 mg/day after 6 months of previous LAM treatment, 52 weeks | Placebo, 26 weeks | Diarrhea | 26/26 | 3/60 2/65 | 5/3 | 1.63 (0.28; 9.39) | 0.02 (-0.05; 0.09) | 52
Tassopoulos, 1999^49^ Lamivudine, 100 mg/day after 6 months of previous LAM treatment, 52 weeks | Placebo, 26 weeks | Tonsillitis | 26/26 | 1/60 0/65 | 2/0 | 3.25 (0.13; 78.18) | 0.02 (-0.03; 0.06) | 60
Tassopoulos, 1999^49^ Lamivudine, 100 mg/day after 6 months of previous LAM treatment, 52 weeks | Placebo, 26 weeks | Dyspeptic symptoms | 26/26 | 2/60 1/65 | 3/2 | 2.17 (0.20; 23.29) | 0.02 (-0.04; 0.07) | 56
Tassopoulos, 1999^49^ Lamivudine, 100 mg/day after 6 months of previous LAM treatment, 52 weeks | Placebo, 26 weeks | At least 1 adverse event | 26/26 | 28/60 40/65 | 47/62 | 0.76 (0.54; 1.06) | -0.15 (-0.32; 0.02) | -7
Tassopoulos, 1999^49^ Lamivudine, 100 mg/day after 6 months of previous LAM treatment, 52 weeks | Placebo, 26 weeks | Headache | 52/26 | 10/60 12/65 | 17/18 | 0.90 (0.42; 1.93) | -0.02 (-0.15; 0.12) | -56
Tassopoulos, 1999^49^ Lamivudine, 100 mg/day after 6 months of previous LAM treatment, 52 weeks | Placebo, 26 weeks | Malaise and fatigue | 52/26 | 11/60 8/65 | 18/12 | 1.49 (0.64; 3.45) | 0.06 (-0.07; 0.19) | 17
Tassopoulos, 1999^49^ Lamivudine, 100 mg/day after 6 months of previous LAM treatment, 52 weeks | Placebo, 26 weeks | Abdominal discomfort and pain | 52/26 | 6/60 8/65 | 10/12 | 0.81 (0.30; 2.21) | -0.02 (-0.13; 0.09) | -43
Tassopoulos, 1999^49^ Lamivudine, 100 mg/day after 6 months of previous LAM treatment, 52 weeks | Placebo, 26 weeks | Temperature regulation disturbance | 52/26 | 5/60 4/65 | 8/6 | 1.35 (0.38; 4.81) | 0.02 (-0.07; 0.11) | 46
Tassopoulos, 1999^49^ Lamivudine, 100 mg/day after 6 months of previous LAM treatment, 52 weeks | Placebo, 26 weeks | Cough | 52/26 | 5/60 3/65 | 8/5 | 1.81 (0.45; 7.23) | 0.04 (-0.05; 0.12) | 27
Tassopoulos, 1999^49^ Lamivudine, 100 mg/day after 6 months of previous LAM treatment, 52 weeks | Placebo, 26 weeks | Viral respiratory infections | 52/26 | 4/60 2/65 | 7/3 | 2.17 (0.41; 11.40) | 0.04 (-0.04; 0.11) | 28
Tassopoulos, 1999^49^ Lamivudine, 100 mg/day after 6 months of previous LAM treatment, 52 weeks | Placebo, 26 weeks | Gastrointestinal infections | 52/26 | 3/60 3/65 | 5/5 | 1.08 (0.23; 5.16) | 0.00 (-0.07; 0.08) | 260
Tassopoulos, 1999^49^ Lamivudine, 100 mg/day after 6 months of previous LAM treatment, 52 weeks | Placebo, 26 weeks | Musculoskeletal pain | 52/26 | 2/60 4/65 | 3/6 | 0.54 (0.10; 2.85) | -0.03 (-0.10; 0.05) | -35
Tassopoulos, 1999^49^ Lamivudine, 100 mg/day after 6 months of previous LAM treatment, 52 weeks | Placebo, 26 weeks | Nausea and vomiting | 52/26 | 5/60 1/65 | 8/2 | 5.42 (0.65; 45.04) | 0.07 (-0.01; 0.14) | 15
Tassopoulos, 1999^49^ Lamivudine, 100 mg/day after 6 months of previous LAM treatment, 52 weeks | Placebo, 26 weeks | Vertigo | 52/26 | 2/60 4/65 | 3/6 | 0.54 (0.10; 2.85) | -0.03 (-0.10; 0.05) | -35
Tassopoulos, 1999^49^ Lamivudine, 100 mg/day after 6 months of previous LAM treatment, 52 weeks | Placebo, 26 weeks | Diarrhea | 52/26 | 3/60 2/65 | 5/3 | 1.63 (0.28; 9.39) | 0.02 (-0.05; 0.09) | 52
Tassopoulos, 1999^49^ Lamivudine, 100 mg/day after 6 months of previous LAM treatment, 52 weeks | Placebo, 26 weeks | Tonsillitis | 52/26 | 4/60 0/65 | 7/0 | 9.74 (0.54; 177.14) | 0.07 (0.00; 0.14) | 15
Tassopoulos, 1999^49^ Lamivudine, 100 mg/day after 6 months of previous LAM treatment, 52 weeks | Placebo, 26 weeks | Dyspeptic symptoms | 52/26 | 3/60 1/65 | 5/2 | 3.25 (0.35; 30.40) | 0.03 (-0.03; 0.10) | 29
Tassopoulos, 1999^49^ Lamivudine, 100 mg/day after 6 months of previous LAM treatment, 52 weeks | Placebo, 26 weeks | At least 1 adverse event | 52/26 | 32/60 40/65 | 53/62 | 0.87 (0.64; 1.18) | -0.08 (-0.26; 0.09) | -12
Tassopoulos, 1999^49^ Lamivudine, 100 mg/day after 6 months of previous LAM treatment, 52 weeks | Placebo, 26 weeks | HBV DNA <2.5 pg/mL | 24/24 | 15/60 11/65 | 25/17 | 1.48 (0.74; 2.96) | 0.08 (-0.06; 0.22) | 12
Tassopoulos, 1999^49^ Lamivudine, 100 mg/day after 6 months of previous LAM treatment, 52 weeks | Placebo, 26 weeks | HBV DNA >2.5 pg/mL | 24/24 | 5/60 40/65 | 8/62 | 0.14 (0.06; 0.32) | -0.53 (-0.67; -0.39) | -2
HBsAg loss | 24/24 | 0/60 1/65 | 0/2 | 0.36 (0.01; 8.69) | -0.02 (-0.06; 0.03) | -65
Dienstag, 1999^48^ Lamivudine, 100 mg/day, 52 weeks | Placebo, 52 weeks | ALT normalization | 52/52 | 27/71 5/72 | 38/7 | 5.48 (2.23; 13.42) | 0.31 (0.18; 0.44) | 3
Dienstag, 1999^48^ Lamivudine, 100 mg/day, 52 weeks | Placebo, 52 weeks | Malaise or fatigue | 52/52 | 13/71 14/72 | 19/20 | 0.94 (0.48; 1.86) | -0.01 (-0.14; 0.12) | -88
Dienstag, 1999^48^ Lamivudine, 100 mg/day, 52 weeks | Placebo, 52 weeks | Nausea or vomiting | 52/52 | 6/71 11/72 | 9/15 | 0.55 (0.22; 1.41) | -0.07 (-0.17; 0.04) | -15
Dienstag, 1999^48^ Lamivudine, 100 mg/day, 52 weeks | Placebo, 52 weeks | Headache | 52/52 | 6/71 6/72 | 9/8 | 1.01 (0.34; 3.00) | 0.00 (-0.09; 0.09) | 852
Dienstag, 1999^48^ Lamivudine, 100 mg/day, 52 weeks | Placebo, 52 weeks | Muscle pain | 52/52 | 0/71 6/72 | 0/8 | 0.08 (0.00; 1.36) | -0.08 (-0.15; -0.02) | -12
Dienstag, 1999^48^ Lamivudine, 100 mg/day, 52 weeks | Placebo, 52 weeks | Abdominal discomfort | 52/52 | 3/71 5/72 | 4/7 | 0.61 (0.15; 2.45) | -0.03 (-0.10; 0.05) | -37
Dienstag, 1999^48^ Lamivudine, 100 mg/day, 52 weeks | Placebo, 52 weeks | Sleep disorder | 52/52 | 5/71 3/72 | 7/4 | 1.69 (0.42; 6.81) | 0.03 (-0.05; 0.10) | 35
Dienstag, 1999^48^ Lamivudine, 100 mg/day, 52 weeks | Placebo, 52 weeks | Paresthesias | 52/52 | 2/71 5/72 | 3/7 | 0.41 (0.08; 2.02) | -0.04 (-0.11; 0.03) | -24
Dienstag, 1999^48^ Lamivudine, 100 mg/day, 52 weeks | Placebo, 52 weeks | Rash | 52/52 | 4/71 6/72 | 6/8 | 0.68 (0.20; 2.29) | -0.03 (-0.11; 0.06) | -37
Dienstag, 1999^48^ Lamivudine, 100 mg/day, 52 weeks | Placebo, 52 weeks | Diarrhea | 52/52 | 4/71 4/72 | 6/6 | 1.01 (0.26; 3.90) | 0.00 (-0.07; 0.08) | 1278
Dienstag, 1999^48^ Lamivudine, 100 mg/day, 52 weeks | Placebo, 52 weeks | Grade III or IV laboratory abnormalities in ALT | 52/52 | 7/71 9/72 | 10/13 | 0.79 (0.31; 2.00) | -0.03 (-0.13; 0.08) | -38
Dienstag, 1999^48^ Lamivudine, 100 mg/day, 52 weeks | Placebo, 52 weeks | Grade III or IV laboratory abnormalities in albumin | 52/52 | 0/71 2/72 | 0/3 | 0.20 (0.01; 4.15) | -0.03 (-0.07; 0.02) | -36
Dienstag, 1999^48^ Lamivudine, 100 mg/day, 52 weeks | Placebo, 52 weeks | Grade III or IV laboratory abnormalities in amylase | 52/52 | 0/71 1/72 | 0/1 | 0.34 (0.01; 8.16) | -0.01 (-0.05; 0.02) | -72
Dienstag, 1999^48^ Lamivudine, 100 mg/day, 52 weeks | Placebo, 52 weeks | Grade III or IV laboratory abnormalities in lipase | 52/52 | 6/71 5/72 | 9/7 | 1.22 (0.39; 3.81) | 0.02 (-0.07; 0.10) | 66
Dienstag, 1999^48^ Lamivudine, 100 mg/day, 52 weeks | Placebo, 52 weeks | Grade III or IV laboratory abnormalities in creatine kinase | 52/52 | 6/71 3/72 | 9/4 | 2.03 (0.53; 7.80) | 0.04 (-0.04; 0.12) | 23
Dienstag, 1999^48^ Lamivudine, 100 mg/day, 52 weeks | Placebo, 52 weeks | Grade III or IV laboratory abnormalities in platelets | 52/52 | 0/71 2/72 | 0/3 | 0.20 (0.01; 4.15) | -0.03 (-0.07; 0.02) | -36
Dienstag, 1999^48^ Lamivudine, 100 mg/day, 52 weeks | Placebo, 52 weeks | Grade III abnormality in ALT | 52/52 | 7/71 9/72 | 10/12 | 0.79 (0.31; 2.00) | -0.03 (-0.13; 0.08) | -38
Dienstag, 1999^48^ Lamivudine, 100 mg/day, 52 weeks | Placebo, 52 weeks | Grade IV abnormality in ALT | 52/52 | 0/71 0/72 | | | 0.00 (-0.03; 0.03)
Dienstag, 1999^48^ Lamivudine, 100 mg/day, 52 weeks | Placebo, 52 weeks | ALT >2 times above baseline levels | 52/52 | 18/71 19/72 | 25/26 | 0.96 (0.55; 1.67) | -0.01 (-0.15; 0.13) | -96
Dienstag, 1999^48^ Lamivudine, 100 mg/day, 52 weeks | Placebo, 52 weeks | ALT >3 times above baseline levels | 52/52 | 7/71 9/72 | 10/12 | 0.79 (0.31; 2.00) | -0.03 (-0.13; 0.08) | -38
Dienstag, 1999^48^ Lamivudine, 100 mg/day, 52 weeks | Placebo, 52 weeks | ALT >2 times above baseline levels and >500 U/liter | 52/52 | 1/71 7/72 | 1/10 | 0.14 (0.02; 1.15) | -0.08 (-0.16; -0.01) | -12
Dienstag, 1999^48^ Lamivudine, 100 mg/day, 52 weeks | Placebo, 52 weeks | ALT >2 times above baseline levels and bilirubin »2 times above baseline levels | 52/52 | 0/71 0/72 | | | 0.00 (-0.03; 0.03)
Dienstag, 1999^48^ Lamivudine, 100 mg/day, 52 weeks | Placebo, 52 weeks | Grade III abnormality in ALT | 68/68 | 14/71 4/72 | 20/6 | 3.55 (1.23; 10.26) | 0.14 (0.04; 0.25) | 7
Dienstag, 1999^48^ Lamivudine, 100 mg/day, 52 weeks | Placebo, 52 weeks | Grade IV abnormality in ALT | 68/68 | 2/71 1/72 | 3/1 | 2.03 (0.19; 21.87) | 0.01 (-0.03; 0.06) | 70
Dienstag, 1999^48^ Lamivudine, 100 mg/day, 52 weeks | Placebo, 52 weeks | ALT >2 times above baseline levels | 68/68 | 19/71 13/72 | 27/18 | 1.48 (0.79; 2.77) | 0.09 (-0.05; 0.22) | 11
Dienstag, 1999^48^ Lamivudine, 100 mg/day, 52 weeks | Placebo, 52 weeks | ALT >3 times above baseline levels | 68/68 | 16/71 5/72 | 23/7 | 3.25 (1.26; 8.38) | 0.16 (0.04; 0.27) | 6
Dienstag, 1999^48^ Lamivudine, 100 mg/day, 52 weeks | Placebo, 52 weeks | ALT >2 times above baseline levels and >500 U/liter | 68/68 | 12/71 6/72 | 17/8 | 2.03 (0.81; 5.11) | 0.09 (-0.02; 0.19) | 12
Dienstag, 1999^48^ Lamivudine, 100 mg/day, 52 weeks | Placebo, 52 weeks | ALT >2 times above baseline levels and bilirubin >2 times above baseline levels | 68/68 | 1/71 1/72 | 1/1 | 1.01 (0.06; 15.90) | 0.00 (-0.04; 0.04) | 5112
Dienstag, 1999^48^ Lamivudine, 100 mg/day, 52 weeks | Placebo, 52 weeks | Reduction of at least 2 points in HAI score | 52/52 | 34/71 16/72 | 48/22 | 2.15 (1.31; 3.54) | 0.26 (0.11; 0.41) | 4
Dienstag, 1999^48^ Lamivudine, 100 mg/day, 52 weeks | Placebo, 52 weeks | Histological worsening, defined as an increase of at least 2 points in HAI score | 52/52 | 7/71 17/72 | 10/24 | 0.42 (0.18; 0.95) | -0.14 (-0.26; -0.02) | -7
Dienstag, 1999^48^ Lamivudine, 100 mg/day, 52 weeks | Placebo, 52 weeks | Decrease in necroinflammatory activity | 52/52 | 42/71 24/72 | 59/33 | 1.77 (1.21; 2.59) | 0.26 (0.10; 0.42) | 4
Dienstag, 1999^48^ Lamivudine, 100 mg/day, 52 weeks | Placebo, 52 weeks | Increased fibrosis | 52/52 | 3/71 14/72 | 4/19 | 0.22 (0.07; 0.72) | -0.15 (-0.25; -0.05) | -7
Dienstag, 1999^48^ Lamivudine, 100 mg/day, 52 weeks | Placebo, 52 weeks | Odds ratio of improvement of at least 2 points in the score on HAI after adjustment for the baseline ALT levels, serum HBV DNA levels, HAI score, and race | 52/52 | 0/71 0/72 | | 7.50 (2.70; 20.90)
Dienstag, 1999^48^ Lamivudine, 100 mg/day, 52 weeks | Placebo, 52 weeks | Undetectable HBV DNA | 52/52 | 62/71 23/72 | 87/32 | 2.73 (1.93; 3.87) | 0.55 (0.42; 0.69) | 2
Dienstag, 1999^48^ Lamivudine, 100 mg/day, 52 weeks | Placebo, 52 weeks | Sustained suppression of serum HBV DNA levels | 52/52 | 28/71 11/72 | 39/15 | 2.58 (1.39; 4.78) | 0.24 (0.10; 0.38) | 4
Dienstag, 1999^48^ Lamivudine, 100 mg/day, 52 weeks | Placebo, 52 weeks | HBeAg seroconversion | 52/52 | 11/71 4/72 | 15/6 | 2.79 (0.93; 8.35) | 0.10 (0.00; 0.20) | 10
Dienstag, 1999^48^ Lamivudine, 100 mg/day, 52 weeks | Placebo, 52 weeks | Lost serum HBeAg | 52/52 | 21/71 8/72 | 30/11 | 2.66 (1.26; 5.61) | 0.18 (0.06; 0.31) | 5
Dienstag, 1999^48^ Lamivudine, 100 mg/day, 52 weeks | Placebo, 52 weeks | HBeAg seroconversion | 68/68 | 11/71 6/72 | 15/8 | 1.86 (0.73; 4.76) | 0.07 (-0.03; 0.18) | 14
Dienstag, 1999^48^ Lamivudine, 100 mg/day, 52 weeks | Placebo, 52 weeks | Lost serum HBeAg | 68/68 | 19/71 11/72 | 27/15 | 1.75 (0.90; 3.41) | 0.11 (-0.02; 0.25) | 9
Loss of serum HBsAg | 68/68 | 1/71 0/72 | 1/0 | 3.04 (0.13; 73.44) | 0.01 (-0.02; 0.05) | 71
Liaw, 2000^110^ Lamivudine, 100 mg/day during second year after 100mg during the first year, 104 weeks | Lamivudine, 25 mg/day during the second year after 25mg/day LAM during the first year, 104 weeks | Viral respiratory infection | 104/104 | 23/93 31/101 | 25/31 | 0.81 (0.51; 1.28) | -0.06 (-0.19; 0.07) | -17
Liaw, 2000^110^ Lamivudine, 100 mg/day during second year after 100mg during the first year, 104 weeks | Lamivudine, 25 mg/day during the second year after 25mg/day LAM during the first year, 104 weeks | Malaise and fatigue | 104/104 | 18/93 16/101 | 19/16 | 1.22 (0.66; 2.25) | 0.04 (-0.07; 0.14) | 28
Liaw, 2000^110^ Lamivudine, 100 mg/day during second year after 100mg during the first year, 104 weeks | Lamivudine, 25 mg/day during the second year after 25mg/day LAM during the first year, 104 weeks | Abdominal discomfort and pain | 104/104 | 18/93 23/101 | 19/23 | 0.85 (0.49; 1.47) | -0.03 (-0.15; 0.08) | -29
Liaw, 2000^110^ Lamivudine, 100 mg/day during second year after 100mg during the first year, 104 weeks | Lamivudine, 25 mg/day during the second year after 25mg/day LAM during the first year, 104 weeks | Cough | 104/104 | 21/93 26/101 | 23/26 | 0.88 (0.53; 1.45) | -0.03 (-0.15; 0.09) | -32
Liaw, 2000^110^ Lamivudine, 100 mg/day during second year after 100mg during the first year, 104 weeks | Lamivudine, 25 mg/day during the second year after 25mg/day LAM during the first year, 104 weeks | Ear, nose, and throat infection | 104/104 | 18/93 24/101 | 19/24 | 0.81 (0.47; 1.40) | -0.04 (-0.16; 0.07) | -23
Liaw, 2000^110^ Lamivudine, 100 mg/day during second year after 100mg during the first year, 104 weeks | Lamivudine, 25 mg/day during the second year after 25mg/day LAM during the first year, 104 weeks | Headache | 104/104 | 17/93 15/101 | 18/15 | 1.23 (0.65; 2.32) | 0.03 (-0.07; 0.14) | 29
Liaw, 2000^110^ Lamivudine, 100 mg/day during second year after 100mg during the first year, 104 weeks | Lamivudine, 25 mg/day during the second year after 25mg/day LAM during the first year, 104 weeks | Throat and tonsil discomfort/pain | 104/104 | 20/93 23/101 | 22/23 | 0.94 (0.56; 1.60) | -0.01 (-0.13; 0.10) | -79
Liaw, 2000^110^ Lamivudine, 100 mg/day during second year after 100mg during the first year, 104 weeks | Lamivudine, 25 mg/day during the second year after 25mg/day LAM during the first year, 104 weeks | Abnormal liver function test results | 104/104 | 13/93 12/101 | 14/12 | 1.18 (0.57; 2.45) | 0.02 (-0.07; 0.12) | 48
Liaw, 2000^110^ Lamivudine, 100 mg/day during second year after 100mg during the first year, 104 weeks | Lamivudine, 25 mg/day during the second year after 25mg/day LAM during the first year, 104 weeks | Diarrhea | 104/104 | 20/93 20/101 | 22/20 | 1.09 (0.63; 1.89) | 0.02 (-0.10; 0.13) | 59
Liaw, 2000^110^ Lamivudine, 100 mg/day during second year after 100mg during the first year, 104 weeks | Lamivudine, 25 mg/day during the second year after 25mg/day LAM during the first year, 104 weeks | Nasal signs and symptoms | 104/104 | 9/93 11/101 | 10/11 | 0.89 (0.39; 2.05) | -0.01 (-0.10; 0.07) | -82
Liaw, 2000^110^ Lamivudine, 100 mg/day during second year after 100mg during the first year, 104 weeks | Lamivudine, 25 mg/day during the second year after 25mg/day LAM during the first year, 104 weeks | Temperature regulation disturbance | 104/104 | 9/93 8/101 | 10/8 | 1.22 (0.49; 3.03) | 0.02 (-0.06; 0.10) | 57
Liaw, 2000^110^ Lamivudine, 100 mg/day during second year after 100mg during the first year, 104 weeks | Lamivudine, 25 mg/day during the second year after 25mg/day LAM during the first year, 104 weeks | Dizziness | 104/104 | 7/93 6/101 | 8/6 | 1.27 (0.44; 3.63) | 0.02 (-0.05; 0.09) | 63
Liaw, 2000^110^ Lamivudine, 100 mg/day during second year after 100mg during the first year, 104 weeks | Lamivudine, 25 mg/day during the second year after 25mg/day LAM during the first year, 104 weeks | Abdominal distention | 104/104 | 7/93 8/101 | 8/8 | 0.95 (0.36; 2.52) | 0.00 (-0.08; 0.07) | -254
Liaw, 2000^110^ Lamivudine, 100 mg/day during second year after 100mg during the first year, 104 weeks | Lamivudine, 25 mg/day during the second year after 25mg/day LAM during the first year, 104 weeks | Nausea and vomiting | 104/104 | 10/93 7/101 | 11/7 | 1.55 (0.62; 3.91) | 0.04 (-0.04; 0.12) | 26
Liaw, 2000^110^ Lamivudine, 100 mg/day during second year after 100mg during the first year, 104 weeks | Musculoskeletal pain | 104/104 | 8/93 7/101 | 9/7 | 1.24 (0.47; 3.29) | 0.02 (-0.06; 0.09) | 60
Liaw, 2000^110^ Lamivudine, 100 mg/day during second year after 100mg during the first year, 104 weeks | Placebo, during the second year after 100mg/day LAM during the first year, 52 weeks | Viral respiratory infection | 104/104 | 23/93 16/41 | 25/40 | 0.63 (0.38; 1.07) | -0.14 (-0.32; 0.03) | -7
Liaw, 2000^110^ Lamivudine, 100 mg/day during second year after 100mg during the first year, 104 weeks | Placebo, during the second year after 100mg/day LAM during the first year, 52 weeks | Malaise and fatigue | 104/104 | 18/93 7/41 | 19/18 | 1.13 (0.51; 2.50) | 0.02 (-0.12; 0.16) | 44
Liaw, 2000^110^ Lamivudine, 100 mg/day during second year after 100mg during the first year, 104 weeks | Placebo, during the second year after 100mg/day LAM during the first year, 52 weeks | Abdominal discomfort and pain | 104/104 | 18/93 7/41 | 19/18 | 1.13 (0.51; 2.50) | 0.02 (-0.12; 0.16) | 44
Liaw, 2000^110^ Lamivudine, 100 mg/day during second year after 100mg during the first year, 104 weeks | Placebo, during the second year after 100mg/day LAM during the first year, 52 weeks | Cough | 104/104 | 21/93 4/41 | 23/10 | 2.31 (0.85; 6.32) | 0.13 (0.00; 0.25) | 8
Liaw, 2000^110^ Lamivudine, 100 mg/day during second year after 100mg during the first year, 104 weeks | Placebo, during the second year after 100mg/day LAM during the first year, 52 weeks | Ear, nose, and throat infection | 104/104 | 18/93 8/41 | 19/20 | 0.99 (0.47; 2.09) | 0.00 (-0.15; 0.14) | -635
Liaw, 2000^110^ Lamivudine, 100 mg/day during second year after 100mg during the first year, 104 weeks | Placebo, during the second year after 100mg/day LAM during the first year, 52 weeks | Headache | 104/104 | 17/93 6/41 | 18/15 | 1.25 (0.53; 2.94) | 0.04 (-0.10; 0.17) | 27
Liaw, 2000^110^ Lamivudine, 100 mg/day during second year after 100mg during the first year, 104 weeks | Placebo, during the second year after 100mg/day LAM during the first year, 52 weeks | Throat and tonsil discomfort/pain | 104/104 | 20/93 7/41 | 22/18 | 1.26 (0.58; 2.74) | 0.04 (-0.10; 0.19) | 23
Liaw, 2000^110^ Lamivudine, 100 mg/day during second year after 100mg during the first year, 104 weeks | Placebo, during the second year after 100mg/day LAM during the first year, 52 weeks | Abnormal liver function test results | 104/104 | 13/93 12/41 | 14/30 | 0.48 (0.24; 0.96) | -0.15 (-0.31; 0.00) | -7
Liaw, 2000^110^ Lamivudine, 100 mg/day during second year after 100mg during the first year, 104 weeks | Placebo, during the second year after 100mg/day LAM during the first year, 52 weeks | Diarrhea | 104/104 | 20/93 9/41 | 22/23 | 0.98 (0.49; 1.96) | 0.00 (-0.16; 0.15) | -224
Liaw, 2000^110^ Lamivudine, 100 mg/day during second year after 100mg during the first year, 104 weeks | Placebo, during the second year after 100mg/day LAM during the first year, 52 weeks | Nasal signs and symptoms | 104/104 | 9/93 2/41 | 10/5 | 1.98 (0.45; 8.78) | 0.05 (-0.04; 0.14) | 21
Liaw, 2000^110^ Lamivudine, 100 mg/day during second year after 100mg during the first year, 104 weeks | Placebo, during the second year after 100mg/day LAM during the first year, 52 weeks | Temperature regulation disturbance | 104/104 | 9/93 3/41 | 10/8 | 1.32 (0.38; 4.63) | 0.02 (-0.08; 0.12) | 42
Liaw, 2000^110^ Lamivudine, 100 mg/day during second year after 100mg during the first year, 104 weeks | Placebo, during the second year after 100mg/day LAM during the first year, 52 weeks | Dizziness | 104/104 | 7/93 4/41 | 8/10 | 0.77 (0.24; 2.49) | -0.02 (-0.13; 0.08) | -45
Liaw, 2000^110^ Lamivudine, 100 mg/day during second year after 100mg during the first year, 104 weeks | Placebo, during the second year after 100mg/day LAM during the first year, 52 weeks | Abdominal distention | 104/104 | 7/93 1/41 | 8/3 | 3.09 (0.39; 24.28) | 0.05 (-0.02; 0.12) | 20
Liaw, 2000^110^ Lamivudine, 100 mg/day during second year after 100mg during the first year, 104 weeks | Placebo, during the second year after 100mg/day LAM during the first year, 52 weeks | Nausea and vomiting | 104/104 | 10/93 3/41 | 11/8 | 1.47 (0.43; 5.06) | 0.03 (-0.07; 0.14) | 29
Liaw, 2000^110^ Lamivudine, 100 mg/day during second year after 100mg during the first year, 104 weeks | Musculoskeletal pain | 104/104 | 8/93 1/41 | 9/3 | 3.53 (0.46; 27.29) | 0.06 (-0.01; 0.14) | 16
Liaw, 2000^110^ Lamivudine, 100 mg/day during second year after 100mg during the first year, 104 weeks | Placebo, during the second year after 25mg/day LAM during the first year, 52 weeks | Viral respiratory infection | 104/104 | 23/93 6/31 | 25/19 | 1.28 (0.57; 2.85) | 0.05 (-0.11; 0.22) | 19
Liaw, 2000^110^ Lamivudine, 100 mg/day during second year after 100mg during the first year, 104 weeks | Placebo, during the second year after 25mg/day LAM during the first year, 52 weeks | Malaise and fatigue | 104/104 | 18/93 10/31 | 19/32 | 0.60 (0.31; 1.16) | -0.13 (-0.31; 0.05) | -8
Liaw, 2000^110^ Lamivudine, 100 mg/day during second year after 100mg during the first year, 104 weeks | Placebo, during the second year after 25mg/day LAM during the first year, 52 weeks | Abdominal discomfort and pain | 104/104 | 18/93 7/31 | 19/23 | 0.86 (0.40; 1.86) | -0.03 (-0.20; 0.14) | -31
Liaw, 2000^110^ Lamivudine, 100 mg/day during second year after 100mg during the first year, 104 weeks | Placebo, during the second year after 25mg/day LAM during the first year, 52 weeks | Cough | 104/104 | 21/93 5/31 | 23/16 | 1.40 (0.58; 3.40) | 0.06 (-0.09; 0.22) | 16
Liaw, 2000^110^ Lamivudine, 100 mg/day during second year after 100mg during the first year, 104 weeks | Placebo, during the second year after 25mg/day LAM during the first year, 52 weeks | Ear, nose, and throat infection | 104/104 | 18/93 8/31 | 19/26 | 0.75 (0.36; 1.55) | -0.06 (-0.24; 0.11) | -16
Liaw, 2000^110^ Lamivudine, 100 mg/day during second year after 100mg during the first year, 104 weeks | Placebo, during the second year after 25mg/day LAM during the first year, 52 weeks | Headache | 104/104 | 17/93 10/31 | 18/32 | 0.57 (0.29; 1.10) | -0.14 (-0.32; 0.04) | -7
Liaw, 2000^110^ Lamivudine, 100 mg/day during second year after 100mg during the first year, 104 weeks | Placebo, during the second year after 25mg/day LAM during the first year, 52 weeks | Throat and tonsil discomfort/pain | 104/104 | 20/93 5/31 | 22/16 | 1.33 (0.55; 3.25) | 0.05 (-0.10; 0.21) | 19
Liaw, 2000^110^ Lamivudine, 100 mg/day during second year after 100mg during the first year, 104 weeks | Placebo, during the second year after 25mg/day LAM during the first year, 52 weeks | Abnormal liver function test results | 104/104 | 13/93 9/31 | 14/29 | 0.48 (0.23; 1.02) | -0.15 (-0.33; 0.02) | -7
Liaw, 2000^110^ Lamivudine, 100 mg/day during second year after 100mg during the first year, 104 weeks | Placebo, during the second year after 25mg/day LAM during the first year, 52 weeks | Diarrhea | 104/104 | 20/93 5/31 | 22/16 | 1.33 (0.55; 3.25) | 0.05 (-0.10; 0.21) | 19
Liaw, 2000^110^ Lamivudine, 100 mg/day during second year after 100mg during the first year, 104 weeks | Placebo, during the second year after 25mg/day LAM during the first year, 52 weeks | Nasal signs and symptoms | 104/104 | 9/93 2/31 | 10/6 | 1.50 (0.34; 6.57) | 0.03 (-0.07; 0.14) | 31
Liaw, 2000^110^ Lamivudine, 100 mg/day during second year after 100mg during the first year, 104 weeks | Placebo, during the second year after 25mg/day LAM during the first year, 52 weeks | Temperature regulation disturbance | 104/104 | 9/93 2/31 | 10/6 | 1.50 (0.34; 6.57) | 0.03 (-0.07; 0.14) | 31
Liaw, 2000^110^ Lamivudine, 100 mg/day during second year after 100mg during the first year, 104 weeks | Placebo, during the second year after 25mg/day LAM during the first year, 52 weeks | Dizziness | 104/104 | 7/93 3/31 | 8/10 | 0.78 (0.21; 2.83) | -0.02 (-0.14; 0.10) | -46
Liaw, 2000^110^ Lamivudine, 100 mg/day during second year after 100mg during the first year, 104 weeks | Placebo, during the second year after 25mg/day LAM during the first year, 52 weeks | Abdominal distention | 104/104 | 7/93 4/31 | 8/13 | 0.58 (0.18; 1.86) | -0.05 (-0.18; 0.08) | -19
Liaw, 2000^110^ Lamivudine, 100 mg/day during second year after 100mg during the first year, 104 weeks | Placebo, during the second year after 25mg/day LAM during the first year, 52 weeks | Nausea and vomiting | 104/104 | 10/93 1/31 | 11/3 | 3.33 (0.44; 25.00) | 0.08 (-0.01; 0.16) | 13
Musculoskeletal pain | 104/104 | 8/93 2/31 | 9/6 | 1.33 (0.30; 5.95) | 0.02 (-0.08; 0.13) | 46
Liaw, 2000^110^ Lamivudine, 25 mg/day during the second year after 25mg/day LAM during the first year, 104 weeks | Placebo, during the second year after 100mg/day LAM during the first year, 52 weeks | Viral respiratory infection | 104/104 | 31/101 16/41 | 31/40 | 0.79 (0.49; 1.27) | -0.08 (-0.26; 0.09) | -12
Liaw, 2000^110^ Lamivudine, 25 mg/day during the second year after 25mg/day LAM during the first year, 104 weeks | Placebo, during the second year after 100mg/day LAM during the first year, 52 weeks | Malaise and fatigue | 104/104 | 16/101 7/41 | 16/18 | 0.93 (0.41; 2.09) | -0.01 (-0.15; 0.12) | -81
Liaw, 2000^110^ Lamivudine, 25 mg/day during the second year after 25mg/day LAM during the first year, 104 weeks | Placebo, during the second year after 100mg/day LAM during the first year, 52 weeks | Abdominal discomfort and pain | 104/104 | 23/101 7/41 | 23/18 | 1.33 (0.62; 2.86) | 0.06 (-0.08; 0.20) | 18
Liaw, 2000^110^ Lamivudine, 25 mg/day during the second year after 25mg/day LAM during the first year, 104 weeks | Placebo, during the second year after 100mg/day LAM during the first year, 52 weeks | Cough | 104/104 | 26/101 4/41 | 26/10 | 2.64 (0.98; 7.09) | 0.16 (0.04; 0.28) | 6
Liaw, 2000^110^ Lamivudine, 25 mg/day during the second year after 25mg/day LAM during the first year, 104 weeks | Placebo, during the second year after 100mg/day LAM during the first year, 52 weeks | Ear, nose, and throat infection | 104/104 | 24/101 8/41 | 24/20 | 1.22 (0.60; 2.48) | 0.04 (-0.10; 0.19) | 24
Liaw, 2000^110^ Lamivudine, 25 mg/day during the second year after 25mg/day LAM during the first year, 104 weeks | Placebo, during the second year after 100mg/day LAM during the first year, 52 weeks | Headache | 104/104 | 15/101 6/41 | 15/15 | 1.01 (0.42; 2.43) | 0.00 (-0.13; 0.13) | 460
Liaw, 2000^110^ Lamivudine, 25 mg/day during the second year after 25mg/day LAM during the first year, 104 weeks | Placebo, during the second year after 100mg/day LAM during the first year, 52 weeks | Throat and tonsil discomfort/pain | 104/104 | 23/101 7/41 | 23/18 | 1.33 (0.62; 2.86) | 0.06 (-0.08; 0.20) | 18
Liaw, 2000^110^ Lamivudine, 25 mg/day during the second year after 25mg/day LAM during the first year, 104 weeks | Placebo, during the second year after 100mg/day LAM during the first year, 52 weeks | Abnormal liver function test results | 104/104 | 12/101 12/41 | 12/30 | 0.41 (0.20; 0.83) | -0.17 (-0.33; -0.02) | -6
Liaw, 2000^110^ Lamivudine, 25 mg/day during the second year after 25mg/day LAM during the first year, 104 weeks | Placebo, during the second year after 100mg/day LAM during the first year, 52 weeks | Diarrhea | 104/104 | 20/101 9/41 | 20/23 | 0.90 (0.45; 1.81) | -0.02 (-0.17; 0.13) | -47
Liaw, 2000^110^ Lamivudine, 25 mg/day during the second year after 25mg/day LAM during the first year, 104 weeks | Placebo, during the second year after 100mg/day LAM during the first year, 52 weeks | Nasal signs and symptoms | 104/104 | 11/101 2/41 | 11/5 | 2.23 (0.52; 9.64) | 0.06 (-0.03; 0.15) | 17
Liaw, 2000^110^ Lamivudine, 25 mg/day during the second year after 25mg/day LAM during the first year, 104 weeks | Placebo, during the second year after 100mg/day LAM during the first year, 52 weeks | Temperature regulation disturbance | 104/104 | 8/101 3/41 | 8/8 | 1.08 (0.30; 3.88) | 0.01 (-0.09; 0.10) | 166
Liaw, 2000^110^ Lamivudine, 25 mg/day during the second year after 25mg/day LAM during the first year, 104 weeks | Placebo, during the second year after 100mg/day LAM during the first year, 52 weeks | Dizziness | 104/104 | 6/101 4/41 | 6/10 | 0.61 (0.18; 2.05) | -0.04 (-0.14; 0.06) | -26
Liaw, 2000^110^ Lamivudine, 25 mg/day during the second year after 25mg/day LAM during the first year, 104 weeks | Placebo, during the second year after 100mg/day LAM during the first year, 52 weeks | Abdominal distention | 104/104 | 8/101 1/41 | 8/3 | 3.25 (0.42; 25.15) | 0.05 (-0.02; 0.13) | 18
Liaw, 2000^110^ Lamivudine, 25 mg/day during the second year after 25mg/day LAM during the first year, 104 weeks | Placebo, during the second year after 100mg/day LAM during the first year, 52 weeks | Nausea and vomiting | 104/104 | 7/101 3/41 | 7/8 | 0.95 (0.26; 3.49) | 0.00 (-0.10; 0.09) | -259
Liaw, 2000^110^ Lamivudine, 25 mg/day during the second year after 25mg/day LAM during the first year, 104 weeks | Musculoskeletal pain | 104/104 | 7/101 1/41 | 7/3 | 2.84 (0.36; 22.38) | 0.04 (-0.02; 0.11) | 22
Liaw, 2000^110^ Lamivudine, 25 mg/day during the second year after 25mg/day LAM during the first year, 104 weeks | Placebo, during the second year after 25mg/day LAM during the first year, 52 weeks | Viral respiratory infection | 104/104 | 31/101 6/31 | 31/19 | 1.59 (0.73; 3.45) | 0.11 (-0.05; 0.28) | 9
Liaw, 2000^110^ Lamivudine, 25 mg/day during the second year after 25mg/day LAM during the first year, 104 weeks | Placebo, during the second year after 25mg/day LAM during the first year, 52 weeks | Malaise and fatigue | 104/104 | 16/101 10/31 | 16/32 | 0.49 (0.25; 0.97) | -0.16 (-0.34; 0.02) | -6
Liaw, 2000^110^ Lamivudine, 25 mg/day during the second year after 25mg/day LAM during the first year, 104 weeks | Placebo, during the second year after 25mg/day LAM during the first year, 52 weeks | Abdominal discomfort and pain | 104/104 | 23/101 7/31 | 23/23 | 1.01 (0.48; 2.12) | 0.00 (-0.17; 0.17) | 522
Liaw, 2000^110^ Lamivudine, 25 mg/day during the second year after 25mg/day LAM during the first year, 104 weeks | Placebo, during the second year after 25mg/day LAM during the first year, 52 weeks | Cough | 104/104 | 26/101 5/31 | 26/16 | 1.60 (0.67; 3.80) | 0.10 (-0.06; 0.25) | 10
Liaw, 2000^110^ Lamivudine, 25 mg/day during the second year after 25mg/day LAM during the first year, 104 weeks | Placebo, during the second year after 25mg/day LAM during the first year, 52 weeks | Ear, nose, and throat infection | 104/104 | 24/101 8/31 | 24/26 | 0.92 (0.46; 1.84) | -0.02 (-0.20; 0.15) | -49
Liaw, 2000^110^ Lamivudine, 25 mg/day during the second year after 25mg/day LAM during the first year, 104 weeks | Placebo, during the second year after 25mg/day LAM during the first year, 52 weeks | Headache | 104/104 | 15/101 10/31 | 15/32 | 0.46 (0.23; 0.92) | -0.17 (-0.35; 0.00) | -6
Liaw, 2000^110^ Lamivudine, 25 mg/day during the second year after 25mg/day LAM during the first year, 104 weeks | Placebo, during the second year after 25mg/day LAM during the first year, 52 weeks | Throat and tonsil discomfort/pain | 104/104 | 23/101 5/31 | 23/16 | 1.41 (0.59; 3.40) | 0.07 (-0.09; 0.22) | 15
Liaw, 2000^110^ Lamivudine, 25 mg/day during the second year after 25mg/day LAM during the first year, 104 weeks | Placebo, during the second year after 25mg/day LAM during the first year, 52 weeks | Abnormal liver function test results | 104/104 | 12/101 9/31 | 12/29 | 0.41 (0.19; 0.88) | -0.17 (-0.34; 0.00) | -6
Liaw, 2000^110^ Lamivudine, 25 mg/day during the second year after 25mg/day LAM during the first year, 104 weeks | Placebo, during the second year after 25mg/day LAM during the first year, 52 weeks | Diarrhea | 104/104 | 20/101 5/31 | 20/16 | 1.23 (0.50; 3.00) | 0.04 (-0.11; 0.19) | 27
Liaw, 2000^110^ Lamivudine, 25 mg/day during the second year after 25mg/day LAM during the first year, 104 weeks | Placebo, during the second year after 25mg/day LAM during the first year, 52 weeks | Nasal signs and symptoms | 104/104 | 11/101 2/31 | 11/6 | 1.69 (0.40; 7.21) | 0.04 (-0.06; 0.15) | 23
Liaw, 2000^110^ Lamivudine, 25 mg/day during the second year after 25mg/day LAM during the first year, 104 weeks | Placebo, during the second year after 25mg/day LAM during the first year, 52 weeks | Temperature regulation disturbance | 104/104 | 8/101 2/31 | 8/6 | 1.23 (0.27; 5.48) | 0.01 (-0.09; 0.12) | 68
Liaw, 2000^110^ Lamivudine, 25 mg/day during the second year after 25mg/day LAM during the first year, 104 weeks | Placebo, during the second year after 25mg/day LAM during the first year, 52 weeks | Dizziness | 104/104 | 6/101 3/31 | 6/10 | 0.61 (0.16; 2.31) | -0.04 (-0.15; 0.08) | -27
Liaw, 2000^110^ Lamivudine, 25 mg/day during the second year after 25mg/day LAM during the first year, 104 weeks | Placebo, during the second year after 25mg/day LAM during the first year, 52 weeks | Abdominal distention | 104/104 | 8/101 4/31 | 8/13 | 0.61 (0.20; 1.90) | -0.05 (-0.18; 0.08) | -20
Liaw, 2000^110^ Lamivudine, 25 mg/day during the second year after 25mg/day LAM during the first year, 104 weeks | Placebo, during the second year after 25mg/day LAM during the first year, 52 weeks | Nausea and vomiting | 104/104 | 7/101 1/31 | 7/3 | 2.15 (0.27; 16.79) | 0.04 (-0.04; 0.12) | 27
Liaw, 2000^110^ Lamivudine, 25 mg/day during the second year after 25mg/day LAM during the first year, 104 weeks | Musculoskeletal pain | 104/104 | 7/101 2/31 | 7/6 | 1.07 (0.24; 4.91) | 0.00 (-0.09; 0.10) | 209
Liaw, 2000^110^ Lamivudine, 25 mg/day during the second year after 25mg/day LAM during the first year, 104 weeks | Lamivudine, 25 mg/day during the second year after 25mg/day LAM during the first year, 104 weeks | Sustained suppression of serum HBV DNA levels | 104/104 | 47/93 24/101 | 51/24 | 2.13 (1.42; 3.18) | 0.27 (0.14; 0.40) | 4
Liaw, 2000^110^ Lamivudine, 25 mg/day during the second year after 25mg/day LAM during the first year, 104 weeks | Placebo, during the second year after 100mg/day LAM during the first year, 52 weeks | Sustained suppression of serum HBV DNA levels | 104/104 | 47/93 2/41 | 51/5 | 10.36 (2.64; 40.63) | 0.46 (0.34; 0.58) | 2
Liaw, 2000^110^ Lamivudine, 25 mg/day during the second year after 25mg/day LAM during the first year, 104 weeks | Placebo, during the second year after 25mg/day LAM during the first year, 52 weeks | Sustained suppression of serum HBV DNA levels | 104/104 | 47/93 2/31 | 51/6 | 7.83 (2.02; 30.38) | 0.44 (0.31; 0.57) | 2
Liaw, 2000^110^ Lamivudine, 25 mg/day during the second year after 25mg/day LAM during the first year, 104 weeks | Placebo, during the second year after 100mg/day LAM during the first year, 52 weeks | Sustained suppression of serum HBV DNA levels | 104/104 | 24/101 2/41 | 24/5 | 4.87 (1.21; 19.68) | 0.19 (0.08; 0.29) | 5
Placebo, during the second year after 25mg/day LAM during the first year, 52 weeks | Sustained suppression of serum HBV DNA levels | 104/104 | 24/101 2/31 | 24/6 | 3.68 (0.92; 14.72) | 0.17 (0.05; 0.29) | 6
Yao, 1999^112^ Lamivudine, 100 mg/day, 12 weeks | Placebo, 12 weeks | ALT Normalization | 12/12 | 91/322 14/107 | 5/4 | 2.16 (1.29; 3.63) | 0.15 (0.07; 0.23) | 7
Yao, 1999^112^ Lamivudine, 100 mg/day, 12 weeks | Placebo, 12 weeks | At least one adverse effect | 12/12 | 138/322 45/107 | 5/4 | 1.02 (0.79; 1.32) | 0.01 (-0.10; 0.12) | 125
Yao, 1999^112^ Lamivudine, 100 mg/day, 12 weeks | Placebo, 12 weeks | At least one drug related adverse effect | 12/12 | 58/322 13/107 | 5/4 | 1.48 (0.85; 2.60) | 0.06 (-0.02; 0.13) | 17
Yao, 1999^112^ Lamivudine, 100 mg/day, 12 weeks | Placebo, 12 weeks | Fatigue | 12/12 | 18/322 8/107 | 5/4 | 0.75 (0.33; 1.67) | -0.02 (-0.07; 0.04) | -53
Yao, 1999^112^ Lamivudine, 100 mg/day, 12 weeks | Placebo, 12 weeks | Abdominal pain and discomfort | 12/12 | 17/322 3/107 | 5/4 | 1.88 (0.56; 6.30) | 0.02 (-0.01; 0.06) | 40
Yao, 1999^112^ Lamivudine, 100 mg/day, 12 weeks | Placebo, 12 weeks | Nausea, vomiting | 12/12 | 13/322 6/107 | 5/4 | 0.72 (0.28; 1.85) | -0.02 (-0.06; 0.03) | -64
Yao, 1999^112^ Lamivudine, 100 mg/day, 12 weeks | Placebo, 12 weeks | Diarrhea | 12/12 | 13/322 3/107 | 5/4 | 1.44 (0.42; 4.96) | 0.01 (-0.03; 0.05) | 81
Yao, 1999^112^ Lamivudine, 100 mg/day, 12 weeks | Placebo, 12 weeks | Constipation | 12/12 | 1/322 1/107 | 5/4 | 0.33 (0.02; 5.27) | -0.01 (-0.03; 0.01) | -160
Yao, 1999^112^ Lamivudine, 100 mg/day, 12 weeks | Placebo, 12 weeks | Dizziness | 12/12 | 16/322 4/107 | 5/4 | 1.33 (0.45; 3.89) | 0.01 (-0.03; 0.06) | 81
Yao, 1999^112^ Lamivudine, 100 mg/day, 12 weeks | Placebo, 12 weeks | Headache | 12/12 | 14/322 5/107 | 5/4 | 0.93 (0.34; 2.52) | 0.00 (-0.05; 0.04) | -308
Yao, 1999^112^ Lamivudine, 100 mg/day, 12 weeks | Placebo, 12 weeks | Sleep disturbance | 12/12 | 6/322 2/107 | 5/4 | 1.00 (0.20; 4.87) | 0.00 (-0.03; 0.03) | -17241
Yao, 1999^112^ Lamivudine, 100 mg/day, 12 weeks | Placebo, 12 weeks | Upper respiratory viral infection | 12/12 | 11/322 6/107 | 5/4 | 0.61 (0.23; 1.61) | -0.02 (-0.07; 0.03) | -46
Yao, 1999^112^ Lamivudine, 100 mg/day, 12 weeks | Placebo, 12 weeks | Cough | 12/12 | 13/322 2/107 | 5/4 | 2.16 (0.50; 9.42) | 0.02 (-0.01; 0.06) | 46
Yao, 1999^112^ Lamivudine, 100 mg/day, 12 weeks | Placebo, 12 weeks | Liver symptoms | 12/12 | 13/322 5/107 | 5/4 | 0.86 (0.32; 2.37) | -0.01 (-0.05; 0.04) | -157
Yao, 1999^112^ Lamivudine, 100 mg/day, 12 weeks | Placebo, 12 weeks | Muscular or skeletal pain | 12/12 | 4/322 4/107 | 5/4 | 0.33 (0.08; 1.31) | -0.02 (-0.06; 0.01) | -40
Yao, 1999^112^ Lamivudine, 100 mg/day, 12 weeks | Placebo, 12 weeks | Leucopenia | 12/12 | 2/322 0/107 | 5/4 | 1.67 (0.08; 34.55) | 0.01 (-0.01; 0.02) | 161
Yao, 1999^112^ Lamivudine, 100 mg/day, 12 weeks | Placebo, 12 weeks | Rash | 12/12 | 6/322 1/107 | 5/4 | 1.99 (0.24; 16.37) | 0.01 (-0.01; 0.03) | 108
Yao, 1999^112^ Lamivudine, 100 mg/day, 12 weeks | Placebo, 12 weeks | Pruritis | 12/12 | 2/322 0/107 | 5/4 | 1.67 (0.08; 34.55) | 0.01 (-0.01; 0.02) | 161
Yao, 1999^112^ Lamivudine, 100 mg/day, 12 weeks | Placebo, 12 weeks | Negative HBeAg | 12/12 | 23/322 5/107 | 7/5 | 1.53 (0.60; 3.92) | 0.02 (-0.02; 0.07) | 40
HBeAg seroconversion | 12/12 | 17/322 5/107 | 5/4 | 1.13 (0.43; 2.99) | 0.01 (-0.04; 0.05) | 165
Dienstag, 2003^107^ Lamivudine, 100 mg/day, 144 weeks | Lamivudine, 100 mg/day, 96 weeks | Improved (decrease of 2 points) HAI necroinflammatory score | 144/96 | 12/152 36/152 | 8/24 | 0.33 (0.18; 0.62) | -0.16 (-0.24; -0.08) | -6
Dienstag, 2003^107^ Lamivudine, 100 mg/day, 144 weeks | Lamivudine, 100 mg/day, 96 weeks | No change | 144/96 | 38/152 24/152 | 25/16 | 1.58 (1.00; 2.51) | 0.09 (0.00; 0.18) | 11
Worsened | 144/96 | 13/152 3/152 | 9/2 | 4.33 (1.26; 14.90) | 0.07 (0.02; 0.12) | 15
Liaw, 2004^51^ Lamivudine, 100 mg/day, 130 weeks | Placebo, 130 weeks | Hepatocellular carcinoma | 130/130 | 17/436 16/215 | 4/7 | 0.52 (0.27; 1.02) | -0.04 (-0.07; 0.00) | -28
Liaw, 2004^51^ Lamivudine, 100 mg/day, 130 weeks | Placebo, 130 weeks | Liver-related death | 130/130 | 0/436 0/215 | | | 0.00 (-0.01; 0.01)
Liaw, 2004^51^ Lamivudine, 100 mg/day, 130 weeks | Placebo, 130 weeks | Hazard ratio of Hepatocellular carcinoma adjusted for country, sex, baseline ALT level, Child-Pugh score, and Ishak fibrosis score | 130/130 | 0/436 0/215 | | 0.49 (0.25; 0.99)
Liaw, 2004^51^ Lamivudine, 100 mg/day, 130 weeks | Placebo, 130 weeks | Death | 130/130 | 2/436 0/215 | | 2.47 (0.12; 51.25) | 0.00 (0.00; 0.01) | 218
Liaw, 2004^51^ Lamivudine, 100 mg/day, 130 weeks | Placebo, 130 weeks | Overall disease progression | 130/130 | 34/436 38/215 | 8/18 | 0.44 (0.29; 0.68) | -0.10 (-0.16; -0.04) | -10
Liaw, 2004^51^ Lamivudine, 100 mg/day, 130 weeks | Placebo, 130 weeks | Increase in Child-Pugh score | 130/130 | 15/436 19/215 | 3/9 | 0.39 (0.20; 0.75) | -0.05 (-0.10; -0.01) | -19
Liaw, 2004^51^ Lamivudine, 100 mg/day, 130 weeks | Placebo, 130 weeks | Hazard ratio of overall disease progression | 130/130 | 0/436 0/215 | | 0.45 (0.28; 0.73)
Liaw, 2004^51^ Lamivudine, 100 mg/day, 130 weeks | Placebo, 130 weeks | Hazard ratio of Increase in Child-Pugh score adjusted for country, sex, baseline ALT, Child-Pugh score, and Ishak fibrosis score | 130/130 | 0/436 0/215 | | 0.45 (0.22; 0.90)
Liaw, 2004^51^ Lamivudine, 100 mg/day, 130 weeks | Placebo, 130 weeks | Renal insufficiency | 130/130 | 2/436 0/215 | | 2.47 (0.12; 51.25) | 0.00 (0.00; 0.01) | 218
Liaw, 2004^51^ Lamivudine, 100 mg/day, 130 weeks | Placebo, 130 weeks | Bleeding varices | 130/130 | 2/436 3/215 | 0/1 | 0.33 (0.06; 1.95) | -0.01 (-0.03; 0.01) | -107
Liaw, 2004^51^ Lamivudine, 100 mg/day, 130 weeks | Placebo, 130 weeks | Spontaneous bacterial peritonitis | 130/130 | 0/436 0/215 | | | 0.00 (-0.01; 0.01)
Liaw, 2004^51^ Lamivudine, 100 mg/day, 130 weeks | Placebo, 130 weeks | Any serious adverse event | 130/130 | 54/436 38/215 | 12/18 | 0.70 (0.48; 1.03) | -0.05 (-0.11; 0.01) | -19
Liaw, 2004^51^ Lamivudine, 100 mg/day, 130 weeks | Placebo, 130 weeks | Any adverse event | 130/130 | 335/436 178/215 | 77/83 | 0.93 (0.86; 1.01) | -0.06 (-0.12; 0.00) | -17
Liaw, 2004^51^ Lamivudine, 100 mg/day, 130 weeks | Placebo, 130 weeks | Ear, nose, or throat infections | 130/130 | 97/436 44/215 | 22/20 | 1.09 (0.79; 1.49) | 0.02 (-0.05; 0.08) | 56
Liaw, 2004^51^ Lamivudine, 100 mg/day, 130 weeks | Placebo, 130 weeks | Abdominal discomfort or pain | 130/130 | 77/436 43/215 | 18/20 | 0.88 (0.63; 1.24) | -0.02 (-0.09; 0.04) | -43
Liaw, 2004^51^ Lamivudine, 100 mg/day, 130 weeks | Placebo, 130 weeks | Malaise or fatigue | 130/130 | 65/436 42/215 | 15/20 | 0.76 (0.54; 1.09) | -0.05 (-0.11; 0.02) | -22
Liaw, 2004^51^ Lamivudine, 100 mg/day, 130 weeks | Placebo, 130 weeks | Headache | 130/130 | 64/436 21/215 | 15/10 | 1.50 (0.94; 2.39) | 0.05 (0.00; 0.10) | 20
Liaw, 2004^51^ Lamivudine, 100 mg/day, 130 weeks | Placebo, 130 weeks | Cough | 130/130 | 62/436 15/215 | 14/7 | 2.04 (1.19; 3.50) | 0.07 (0.03; 0.12) | 14
Liaw, 2004^51^ Lamivudine, 100 mg/day, 130 weeks | Placebo, 130 weeks | Diarrhea | 130/130 | 33/436 29/215 | 8/13 | 0.56 (0.35; 0.90) | -0.06 (-0.11; -0.01) | -17
Liaw, 2004^51^ Lamivudine, 100 mg/day, 130 weeks | Placebo, 130 weeks | Viral respiratory infections | 130/130 | 39/436 21/215 | 9/10 | 0.92 (0.55; 1.52) | -0.01 (-0.06; 0.04) | -122
YMDD mutations | 130/130 | 209/436 11/215 | 48/5 | 9.37 (5.23; 16.80) | 0.43 (0.37; 0.48) | 2
Kim, 2006^54^ Lamivudine, 100 mg/day after 6 months of previous LAM treatment, 80 weeks | No treatment, 80 weeks | Flare - elevation of ALT >10 × ULN and to >2 the baseline value with detectable HBV DNA | 80/80 | 4/37 6/37 | 11/0 | 0.67 (0.20; 2.17) | -0.05 (-0.21; 0.10) | -18
Kim, 2006^54^ Lamivudine, 100 mg/day after 6 months of previous LAM treatment, 80 weeks | No treatment, 80 weeks | ALT normalization | 80/80 | 2/37 2/37 | 5/5 | 1.00 (0.15; 6.73) | 0.00 (-0.10; 0.10)
Kim, 2006^54^ Lamivudine, 100 mg/day after 6 months of previous LAM treatment, 80 weeks | No treatment, 80 weeks | Hepatic decompensation change in the Child- Turcotte-Pugh score of 2 or more points | 80/80 | 7/37 5/37 | 19/0 | 1.40 (0.49; 4.01) | 0.05 (-0.11; 0.22) | 18
Kim, 2006^54^ Lamivudine, 100 mg/day after 6 months of previous LAM treatment, 80 weeks | No treatment, 80 weeks | Severe decompensation with a Child-Turcotte-Pugh score of >9 | 80/80 | 3/37 3/37 | 8/0 | 1.00 (0.22; 4.64) | 0.00 (-0.12; 0.12)
HBeAg seroconversion | 80/80 | 3/37 6/37 | 8/16 | 0.50 (0.14; 1.85) | -0.08 (-0.23; 0.07) | -12
Chan, 2007^46^ Lamivudine, 100 mg/day, 96 weeks | Placebo, 96 weeks | Normalization of ALT | 96/96 | 66/89 17/47 | 74/36 | 2.05 (1.38; 3.06) | 0.38 (0.22; 0.54) | 3
Chan, 2007^46^ Lamivudine, 100 mg/day, 96 weeks | Placebo, 96 weeks | Normalization of ALT | 120/120 | 53/89 18/47 | 60/38 | 1.55 (1.04; 2.32) | 0.21 (0.04; 0.38) | 5
Chan, 2007^46^ Lamivudine, 100 mg/day, 96 weeks | Placebo, 96 weeks | Undetectable HBV DNA and ALT normalization | 96/96 | 50/89 5/47 | 56/11 | 5.28 (2.26; 12.34) | 0.46 (0.32; 0.59) | 2
Chan, 2007^46^ Lamivudine, 100 mg/day, 96 weeks | Placebo, 96 weeks | Adjusted for baseline HBV DNA and ALT odds ratio of undetectable HBV DNA and ALT normalization of | 96/96 | 0/89 0/47 | | 10.80 (3.80; 30.20)
Chan, 2007^46^ Lamivudine, 100 mg/day, 96 weeks | Placebo, 96 weeks | Undetectable HBV DNA and ALT normalization | 120/120 | 23/89 9/47 | 26/19 | 1.35 (0.68; 2.68) | 0.07 (-0.08; 0.21) | 15
Chan, 2007^46^ Lamivudine, 100 mg/day, 96 weeks | Placebo, 96 weeks | URTI symptoms | 96/96 | 29/89 15/47 | 33/32 | 1.02 (0.61; 1.71) | 0.01 (-0.16; 0.17) | 149
Chan, 2007^46^ Lamivudine, 100 mg/day, 96 weeks | Placebo, 96 weeks | Right upper quadrant discomfort | 96/96 | 15/89 3/47 | 17/6 | 2.64 (0.80; 8.66) | 0.10 (0.00; 0.21) | 10
Chan, 2007^46^ Lamivudine, 100 mg/day, 96 weeks | Placebo, 96 weeks | Dyspepsia | 96/96 | 8/89 4/47 | 9/9 | 1.06 (0.34; 3.33) | 0.00 (-0.09; 0.10) | 209
Chan, 2007^46^ Lamivudine, 100 mg/day, 96 weeks | Placebo, 96 weeks | Headache | 96/96 | 7/89 3/47 | 8/6 | 1.23 (0.33; 4.55) | 0.01 (-0.07; 0.10) | 67
Chan, 2007^46^ Lamivudine, 100 mg/day, 96 weeks | Placebo, 96 weeks | Increased ALT | 96/96 | 11/89 6/47 | 12/13 | 0.97 (0.38; 2.45) | 0.00 (-0.12; 0.11) | -246
Chan, 2007^46^ Lamivudine, 100 mg/day, 96 weeks | Placebo, 96 weeks | Increased ALP | 96/96 | 9/89 6/47 | 10/13 | 0.79 (0.30; 2.09) | -0.03 (-0.14; 0.09) | -38
Chan, 2007^46^ Lamivudine, 100 mg/day, 96 weeks | Placebo, 96 weeks | Increased bilirubin | 96/96 | 1/89 1/47 | 1/2 | 0.53 (0.03; 8.25) | -0.01 (-0.06; 0.04) | -100
Chan, 2007^46^ Lamivudine, 100 mg/day, 96 weeks | Placebo, 96 weeks | Increased CPK | 96/96 | 3/89 3/47 | 3/6 | 0.53 (0.11; 2.52) | -0.03 (-0.11; 0.05) | -33
Chan, 2007^46^ Lamivudine, 100 mg/day, 96 weeks | Placebo, 96 weeks | Increased amylase | 96/96 | 3/89 0/47 | 3/0 | 3.73 (0.20; 70.79) | 0.03 (-0.02; 0.08) | 30
Chan, 2007^46^ Lamivudine, 100 mg/day, 96 weeks | Placebo, 96 weeks | Prolonged PT level | 96/96 | 1/89 3/47 | 1/6 | 0.18 (0.02; 1.65) | -0.05 (-0.13; 0.02) | -19
Chan, 2007^46^ Lamivudine, 100 mg/day, 96 weeks | Placebo, 96 weeks | Low neutrophil count | 96/96 | 0/89 1/47 | 0/2 | 0.18 (0.01; 4.28) | -0.02 (-0.07; 0.03) | -47
Chan, 2007^46^ Lamivudine, 100 mg/day, 96 weeks | Placebo, 96 weeks | Thrombocytopenia | 96/96 | 7/89 3/47 | 8/6 | 1.23 (0.33; 4.55) | 0.01 (-0.07; 0.10) | 67
Chan, 2007^46^ Lamivudine, 100 mg/day, 96 weeks | Placebo, 96 weeks | >2 points improvement in necroinflammatory scores | 96/96 | 14/89 2/47 | 16/4 | 3.70 (0.88; 15.58) | 0.11 (0.02; 0.21) | 9
Chan, 2007^46^ Lamivudine, 100 mg/day, 96 weeks | Placebo, 96 weeks | >2 points worsening in necroinflammatory scores | 96/96 | 2/89 3/47 | 2/6 | 0.35 (0.06; 2.03) | -0.04 (-0.12; 0.04) | -24
Chan, 2007^46^ Lamivudine, 100 mg/day, 96 weeks | Placebo, 96 weeks | >2 points improvement in fibrosis scores | 96/96 | 6/89 0/47 | 7/0 | 6.93 (0.40; 120.47) | 0.07 (0.01; 0.13) | 15
Chan, 2007^46^ Lamivudine, 100 mg/day, 96 weeks | Placebo, 96 weeks | >2 points worsening in fibrosis scores | 96/96 | 1/89 1/47 | 1/2 | 0.53 (0.03; 8.25) | -0.01 (-0.06; 0.04) | -100
Chan, 2007^46^ Lamivudine, 100 mg/day, 96 weeks | Placebo, 96 weeks | HBV DNA <10,000 copies/ml | 96/96 | 52/89 9/47 | 58/19 | 3.05 (1.65; 5.63) | 0.39 (0.24; 0.54) | 3
Chan, 2007^46^ Lamivudine, 100 mg/day, 96 weeks | Placebo, 96 weeks | Undetectable HBV DNA with PCR | 96/96 | 23/89 3/47 | 26/6 | 4.05 (1.28; 12.79) | 0.19 (0.08; 0.31) | 5
Chan, 2007^46^ Lamivudine, 100 mg/day, 96 weeks | Placebo, 96 weeks | HBV DNA <10,000 copies/ml | 120/120 | 29/89 12/47 | 33/26 | 1.28 (0.72; 2.26) | 0.07 (-0.09; 0.23) | 14
Chan, 2007^46^ Lamivudine, 100 mg/day, 96 weeks | Placebo, 96 weeks | Undetectable HBV DNA with PCR | 120/120 | 9/89 1/47 | 10/2 | 4.75 (0.62; 36.39) | 0.08 (0.00; 0.15) | 13
Chan, 2007^46^ Lamivudine, 100 mg/day, 96 weeks | Placebo, 96 weeks | HBsAg loss | 120/120 | 1/89 0/47 | 1/0 | 1.60 (0.07; 38.53) | 0.01 (-0.03; 0.05) | 89
Genotypic resistance | 96/96 | 16/89 1/47 | 18/2 | 8.45 (1.16; 61.76) | 0.16 (0.07; 0.25) | 6
Perrillo, 2002^104^ Lamivudine, 100 mg/day, 52 weeks | Placebo, 52 weeks | HBeAg irrespective of HBV-DNA status | 52/52 | 102/406 20/196 | 25/10 | 2.46 (1.57; 3.85) | 0.15 (0.09; 0.21) | 7
HBeAg and HBV DNA loss | 52/52 | 66/406 14/196 | 16/7 | 2.28 (1.31; 3.95) | 0.09 (0.04; 0.14) | 11
Lai, 2005^72^ Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day + Placebo, 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day, 52 weeks | ALT normalization | 52/52 | 12/19 20/22 | 63/91 | 0.69 (0.48; 1.00) | -0.28 (-0.53; -0.03) | -4
Lai, 2005^72^ Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day + Placebo, 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks | ALT normalization | 52/52 | 12/19 18/22 | 63/82 | 0.77 (0.52; 1.15) | -0.19 (-0.46; 0.08) | -5
Lai, 2005^72^ Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day + Placebo, 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 500 mg/day, 52 weeks | ALT normalization | 52/52 | 12/19 38/44 | 63/86 | 0.73 (0.51; 1.05) | -0.23 (-0.47; 0.01) | -4
Lai, 2005^72^ Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day + Placebo, 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 500 mg/day, 52 weeks | HBV DNA <5 log10 copies/mL and HBeAg loss or normalization of ALT levels | 52/52 | 10/19 34/44 | 53/77 | 0.68 (0.43; 1.07) | -0.25 (-0.50; 0.01) | -4
Lai, 2005^72^ Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day + Placebo, 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day, 52 weeks | At least one adverse event | 52/52 | 13/19 16/22 | 68/73 | 0.94 (0.63; 1.40) | -0.04 (-0.32; 0.24) | -23
Lai, 2005^72^ Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day + Placebo, 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day, 52 weeks | Influenza | 52/52 | 4/19 4/22 | 21/18 | 1.16 (0.33; 4.01) | 0.03 (-0.22; 0.27) | 35
Lai, 2005^72^ Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day + Placebo, 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day, 52 weeks | Headache | 52/52 | 5/19 1/22 | 26/5 | 5.79 (0.74; 45.31) | 0.22 (0.00; 0.43) | 5
Lai, 2005^72^ Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day + Placebo, 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day, 52 weeks | Fatigue | 52/52 | 3/19 1/22 | 16/5 | 3.47 (0.39; 30.68) | 0.11 (-0.07; 0.30) | 9
Lai, 2005^72^ Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day + Placebo, 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day, 52 weeks | Cough | 52/52 | 3/19 2/22 | 16/9 | 1.74 (0.32; 9.32) | 0.07 (-0.14; 0.27) | 15
Lai, 2005^72^ Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day + Placebo, 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day, 52 weeks | Pharyngolaryngeal pain | 52/52 | 3/19 2/22 | 16/9 | 1.74 (0.32; 9.32) | 0.07 (-0.14; 0.27) | 15
Lai, 2005^72^ Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day + Placebo, 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day, 52 weeks | Upper respiratory tract infection | 52/52 | 1/19 3/22 | 5/14 | 0.39 (0.04; 3.41) | -0.08 (-0.26; 0.09) | -12
Lai, 2005^72^ Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day + Placebo, 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day, 52 weeks | Nasopharyngitis | 52/52 | 1/19 1/22 | 5/5 | 1.16 (0.08; 17.28) | 0.01 (-0.13; 0.14) | 139
Lai, 2005^72^ Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day + Placebo, 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day, 52 weeks | Diarrhea | 52/52 | 1/19 2/22 | 5/9 | 0.58 (0.06; 5.89) | -0.04 (-0.19; 0.12) | -26
Lai, 2005^72^ Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day + Placebo, 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day, 52 weeks | Upper abdominal pain | 52/52 | 1/19 1/22 | 5/5 | 1.16 (0.08; 17.28) | 0.01 (-0.13; 0.14) | 139
Lai, 2005^72^ Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day + Placebo, 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day, 52 weeks | Back pain | 52/52 | 0/19 0/22 | | | 0.00 (-0.09; 0.09)
Lai, 2005^72^ Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day + Placebo, 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day, 52 weeks | Dyspepsia | 52/52 | 4/19 0/22 | 21/0 | 10.35 (0.59; 180.66) | 0.21 (0.02; 0.40) | 5
Lai, 2005^72^ Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day + Placebo, 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day, 52 weeks | Dizziness | 52/52 | 1/19 0/22 | 5/0 | 3.45 (0.15; 80.03) | 0.05 (-0.08; 0.18) | 19
Lai, 2005^72^ Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day + Placebo, 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day, 52 weeks | Increased creatine phosphokinase level | 52/52 | 1/19 1/22 | 5/5 | 1.16 (0.08; 17.28) | 0.01 (-0.13; 0.14) | 139
Lai, 2005^72^ Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day + Placebo, 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day, 52 weeks | Nausea | 52/52 | 1/19 1/22 | 5/5 | 1.16 (0.08; 17.28) | 0.01 (-0.13; 0.14) | 139
Lai, 2005^72^ Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day + Placebo, 52 weeks | Depression | 52/52 | 2/19 0/22 | 11/0 | 5.75 (0.29; 112.83) | 0.11 (-0.05; 0.26) | 9
Lai, 2005^72^ Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day + Placebo, 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks | At least one adverse event | 52/52 | 13/19 15/22 | 68/68 | 1.00 (0.66; 1.52) | 0.00 (-0.28; 0.29) | 418
Lai, 2005^72^ Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day + Placebo, 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks | Influenza | 52/52 | 4/19 4/22 | 21/18 | 1.16 (0.33; 4.01) | 0.03 (-0.22; 0.27) | 35
Lai, 2005^72^ Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day + Placebo, 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks | Headache | 52/52 | 5/19 3/22 | 26/14 | 1.93 (0.53; 7.03) | 0.13 (-0.12; 0.37) | 8
Lai, 2005^72^ Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day + Placebo, 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks | Fatigue | 52/52 | 3/19 4/22 | 16/18 | 0.87 (0.22; 3.40) | -0.02 (-0.25; 0.21) | -42
Lai, 2005^72^ Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day + Placebo, 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks | Cough | 52/52 | 3/19 1/22 | 16/5 | 3.47 (0.39; 30.68) | 0.11 (-0.07; 0.30) | 9
Lai, 2005^72^ Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day + Placebo, 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks | Pharyngolaryngeal pain | 52/52 | 3/19 1/22 | 16/5 | 3.47 (0.39; 30.68) | 0.11 (-0.07; 0.30) | 9
Lai, 2005^72^ Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day + Placebo, 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks | Upper respiratory tract infection | 52/52 | 1/19 0/22 | 5/0 | 3.45 (0.15; 80.03) | 0.05 (-0.08; 0.18) | 19
Lai, 2005^72^ Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day + Placebo, 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks | Nasopharyngitis | 52/52 | 1/19 1/22 | 5/5 | 1.16 (0.08; 17.28) | 0.01 (-0.13; 0.14) | 139
Lai, 2005^72^ Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day + Placebo, 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks | Diarrhea | 52/52 | 1/19 1/22 | 5/5 | 1.16 (0.08; 17.28) | 0.01 (-0.13; 0.14) | 139
Lai, 2005^72^ Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day + Placebo, 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks | Upper abdominal pain | 52/52 | 1/19 2/22 | 5/9 | 0.58 (0.06; 5.89) | -0.04 (-0.19; 0.12) | -26
Lai, 2005^72^ Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day + Placebo, 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks | Back pain | 52/52 | 0/19 1/22 | 0/5 | 0.38 (0.02; 8.89) | -0.05 (-0.17; 0.08) | -22
Lai, 2005^72^ Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day + Placebo, 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks | Dyspepsia | 52/52 | 4/19 1/22 | 21/5 | 4.63 (0.57; 37.96) | 0.17 (-0.04; 0.37) | 6
Lai, 2005^72^ Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day + Placebo, 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks | Dizziness | 52/52 | 1/19 1/22 | 5/5 | 1.16 (0.08; 17.28) | 0.01 (-0.13; 0.14) | 139
Lai, 2005^72^ Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day + Placebo, 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks | Increased creatine phosphokinase level | 52/52 | 1/19 1/22 | 5/5 | 1.16 (0.08; 17.28) | 0.01 (-0.13; 0.14) | 139
Lai, 2005^72^ Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day + Placebo, 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks | Nausea | 52/52 | 1/19 1/22 | 5/5 | 1.16 (0.08; 17.28) | 0.01 (-0.13; 0.14) | 139
Lai, 2005^72^ Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day + Placebo, 52 weeks | Depression | 52/52 | 2/19 0/22 | 11/0 | 5.75 (0.29; 112.83) | 0.11 (-0.05; 0.26) | 9
Lai, 2005^72^ Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day + Placebo, 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 500 mg/day, 52 weeks | HBV DNA PCR non detectable | 52/52 | 6/19 27/44 | 32/61 | 0.51 (0.26; 1.04) | -0.30 (-0.55; -0.04) | -3
Lai, 2005^72^ Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day + Placebo, 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 500 mg/day, 52 weeks | HBeAg loss | 52/52 | 5/19 15/44 | 28/33 | 0.77 (0.33; 1.82) | -0.08 (-0.32; 0.16) | -13
Lai, 2005^72^ Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day + Placebo, 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 500 mg/day, 52 weeks | HBeAg seroconversion | 52/52 | 4/19 14/44 | 22/31 | 0.66 (0.25; 1.75) | -0.11 (-0.34; 0.12) | -9
Lai, 2005^72^ Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day + Placebo, 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 500 mg/day, 52 weeks | HBeAg loss and HBV DNA <5 log10 copies/mL | 52/52 | 5/19 14/44 | 26/32 | 0.83 (0.35; 1.97) | -0.06 (-0.30; 0.19) | -18
Virologic break through on treatment increase in HBV DNA levels to >5 log10 copies/mL | 52/52 | 3/19 2/44 | 16/5 | 3.47 (0.63; 19.14) | 0.11 (-0.06; 0.29) | 9
Hadziyannis, 2005^98^ Placebo, 0 placebo after 48 weeks of adefovir therapy, 96 weeks | Adefovir dipivoxil, 10 mg daily after 48 weeks of placebo therapy, 96 weeks | ALT normalization | 96/96 | 12/40 40/60 | 30/67 | 0.45 (0.27; 0.75) | -0.37 (-0.55; -0.18) | -3
Hadziyannis, 2005^98^ Placebo, 0 placebo after 48 weeks of adefovir therapy, 96 weeks | Adefovir dipivoxil, 10 mg daily after 48 weeks of placebo therapy, 96 weeks | Any adverse events | 96/96 | 32/40 41/60 | 80/68 | 1.17 (0.93; 1.48) | 0.12 (-0.05; 0.29) | 9
Hadziyannis, 2005^98^ Placebo, 0 placebo after 48 weeks of adefovir therapy, 96 weeks | Adefovir dipivoxil, 10 mg daily after 48 weeks of placebo therapy, 96 weeks | Headache | 96/96 | 4/40 5/60 | 10/8 | 1.20 (0.34; 4.20) | 0.02 (-0.10; 0.13) | 60
Hadziyannis, 2005^98^ Placebo, 0 placebo after 48 weeks of adefovir therapy, 96 weeks | Adefovir dipivoxil, 10 mg daily after 48 weeks of placebo therapy, 96 weeks | Abdominal pain | 96/96 | 7/40 5/60 | 18/8 | 2.10 (0.72; 6.16) | 0.09 (-0.05; 0.23) | 11
Hadziyannis, 2005^98^ Placebo, 0 placebo after 48 weeks of adefovir therapy, 96 weeks | Adefovir dipivoxil, 10 mg daily after 48 weeks of placebo therapy, 96 weeks | Asthenia | 96/96 | 6/40 3/60 | 15/5 | 3.00 (0.80; 11.31) | 0.10 (-0.02; 0.22) | 10
Hadziyannis, 2005^98^ Placebo, 0 placebo after 48 weeks of adefovir therapy, 96 weeks | Adefovir dipivoxil, 10 mg daily after 48 weeks of placebo therapy, 96 weeks | Flu-like syndrome | 96/96 | 4/40 5/60 | 10/8 | 1.20 (0.34; 4.20) | 0.02 (-0.10; 0.13) | 60
Hadziyannis, 2005^98^ Placebo, 0 placebo after 48 weeks of adefovir therapy, 96 weeks | Adefovir dipivoxil, 10 mg daily after 48 weeks of placebo therapy, 96 weeks | Back pain | 96/96 | 5/40 3/60 | 12/5 | 2.50 (0.63; 9.88) | 0.08 (-0.04; 0.19) | 13
Hadziyannis, 2005^98^ Placebo, 0 placebo after 48 weeks of adefovir therapy, 96 weeks | Adefovir dipivoxil, 10 mg daily after 48 weeks of placebo therapy, 96 weeks | Pain | 96/96 | 2/40 4/60 | 5/7 | 0.75 (0.14; 3.90) | -0.02 (-0.11; 0.08) | -60
Hadziyannis, 2005^98^ Placebo, 0 placebo after 48 weeks of adefovir therapy, 96 weeks | Adefovir dipivoxil, 10 mg daily after 48 weeks of placebo therapy, 96 weeks | Accidental injury | 96/96 | 2/40 2/60 | 5/3 | 1.50 (0.22; 10.22) | 0.02 (-0.06; 0.10) | 60
Hadziyannis, 2005^98^ Placebo, 0 placebo after 48 weeks of adefovir therapy, 96 weeks | Adefovir dipivoxil, 10 mg daily after 48 weeks of placebo therapy, 96 weeks | Diarrhea | 96/96 | 4/40 1/60 | 10/2 | 6.00 (0.70; 51.74) | 0.08 (-0.02; 0.18) | 12
Hadziyannis, 2005^98^ Placebo, 0 placebo after 48 weeks of adefovir therapy, 96 weeks | Adefovir dipivoxil, 10 mg daily after 48 weeks of placebo therapy, 96 weeks | Dyspepsia | 96/96 | 5/40 1/60 | 12/2 | 7.50 (0.91; 61.83) | 0.11 (0.00; 0.22) | 9
Hadziyannis, 2005^98^ Placebo, 0 placebo after 48 weeks of adefovir therapy, 96 weeks | Adefovir dipivoxil, 10 mg daily after 48 weeks of placebo therapy, 96 weeks | Pharyngitis | 96/96 | 8/40 8/60 | 20/13 | 1.50 (0.61; 3.67) | 0.07 (-0.08; 0.22) | 15
Hadziyannis, 2005^98^ Placebo, 0 placebo after 48 weeks of adefovir therapy, 96 weeks | Adefovir dipivoxil, 10 mg daily after 48 weeks of placebo therapy, 96 weeks | Increased cough | 96/96 | 4/40 2/60 | 10/3 | 3.00 (0.58; 15.61) | 0.07 (-0.04; 0.17) | 15
Hadziyannis, 2005^98^ Placebo, 0 placebo after 48 weeks of adefovir therapy, 96 weeks | Adefovir dipivoxil, 10 mg daily after 48 weeks of placebo therapy, 96 weeks | Bronchitis | 96/96 | 1/40 1/60 | 2/2 | 1.50 (0.10; 23.30) | 0.01 (-0.05; 0.07) | 120
Hadziyannis, 2005^98^ Placebo, 0 placebo after 48 weeks of adefovir therapy, 96 weeks | Adefovir dipivoxil, 10 mg daily after 48 weeks of placebo therapy, 96 weeks | Increased ALT levels | 96/96 | 6/40 1/60 | 15/2 | 9.00 (1.13; 71.96) | 0.13 (0.02; 0.25) | 8
Hadziyannis, 2005^98^ Placebo, 0 placebo after 48 weeks of adefovir therapy, 96 weeks | Adefovir dipivoxil, 10 mg daily after 48 weeks of placebo therapy, 96 weeks | Arthralgia | 96/96 | 5/40 1/60 | 12/2 | 7.50 (0.91; 61.83) | 0.11 (0.00; 0.22) | 9
Hadziyannis, 2005^98^ Placebo, 0 placebo after 48 weeks of adefovir therapy, 96 weeks | Adefovir dipivoxil, 10 mg daily after 48 weeks of placebo therapy, 96 weeks | Increased creatinine levels | 96/96 | 0/40 0/60 | | | 0.00 (-0.04; 0.04)
Hadziyannis, 2005^98^ Placebo, 0 placebo after 48 weeks of adefovir therapy, 96 weeks | Adefovir dipivoxil, 10 mg daily after 48 weeks of placebo therapy, 96 weeks | Hematuria | 96/96 | 0/40 1/60 | 0/2 | 0.50 (0.02; 11.88) | -0.02 (-0.07; 0.03) | -60
Hadziyannis, 2005^98^ Placebo, 0 placebo after 48 weeks of adefovir therapy, 96 weeks | Adefovir dipivoxil, 10 mg daily after 48 weeks of placebo therapy, 96 weeks | Kidney calculus | 96/96 | 0/40 1/60 | 0/2 | 0.50 (0.02; 11.88) | -0.02 (-0.07; 0.03) | -60
Hadziyannis, 2005^98^ Placebo, 0 placebo after 48 weeks of adefovir therapy, 96 weeks | Adefovir dipivoxil, 10 mg daily after 48 weeks of placebo therapy, 96 weeks | Kidney pain | 96/96 | 0/40 1/60 | 0/2 | 0.50 (0.02; 11.88) | -0.02 (-0.07; 0.03) | -60
Hadziyannis, 2005^98^ Placebo, 0 placebo after 48 weeks of adefovir therapy, 96 weeks | Adefovir dipivoxil, 10 mg daily after 48 weeks of placebo therapy, 96 weeks | Improvement in Histological scores | 96/96 | 4/40 14/60 | 10/23 | 0.43 (0.15; 1.21) | -0.13 (-0.28; 0.01) | -8
Hadziyannis, 2005^98^ Placebo, 0 placebo after 48 weeks of adefovir therapy, 96 weeks | Adefovir dipivoxil, 10 mg daily after 48 weeks of placebo therapy, 96 weeks | Serum HBV DNA level <1000 log copies/ml | 96/96 | 3/40 37/60 | 8/62 | 0.12 (0.04; 0.37) | -0.54 (-0.69; -0.39) | -2
HBsAg seroconversion | 96/96 | 0/40 1/60 | 0/2 | 0.50 (0.02; 11.88) | -0.02 (-0.07; 0.03) | -60
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks | ALT normalization | 52/52 | 17/21 15/20 | 81/74 | 1.08 (0.78; 1.50) | 0.06 (-0.19; 0.31) | 17
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day, 52 weeks | ALT normalization | 52/52 | 17/21 12/19 | 81/63 | 1.28 (0.86; 1.91) | 0.18 (-0.10; 0.45) | 6
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day, 52 weeks | ALT normalization | 52/52 | 17/21 20/22 | 81/91 | 0.89 (0.70; 1.14) | -0.10 (-0.31; 0.11) | -10
Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks | ALT normalization | 52/52 | 17/21 18/22 | 81/82 | 0.99 (0.74; 1.32) | -0.01 (-0.24; 0.22) | -116
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day, 52 weeks | ALT normalization | 52/52 | 15/20 12/19 | 74/63 | 1.19 (0.78; 1.82) | 0.12 (-0.17; 0.41) | 8
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day, 52 weeks | ALT normalization | 52/52 | 15/20 20/22 | 74/91 | 0.83 (0.62; 1.10) | -0.16 (-0.38; 0.07) | -6
Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks | ALT normalization | 52/52 | 15/20 18/22 | 74/82 | 0.92 (0.67; 1.26) | -0.07 (-0.32; 0.18) | -15
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day +Placebo, 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks | ALT normalization | 52/52 | 20/22 18/22 | 91/82 | 1.11 (0.88; 1.41) | 0.09 (-0.11; 0.29) | 11
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 500 mg/day (both 400mg or 600 mg/day) lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day, 52 weeks | ALT normalization | 52/52 | 32/41 12/19 | 78/63 | 1.24 (0.85; 1.81) | 0.15 (-0.10; 0.40) | 7
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 500 mg/day (both 400mg or 600 mg/day) lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 500 mg/day, 52 weeks | ALT normalization | 52/52 | 32/41 38/44 | 78/86 | 0.90 (0.74; 1.10) | -0.08 (-0.25; 0.08) | -12
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 500 mg/day (both 400mg or 600 mg/day) lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day, 52 weeks | HBV DNA <5 log 10 copies/mL coupled with HBeAg loss or normalization of ALT levels | 52/52 | 26/41 10/19 | 63/53 | 1.20 (0.74; 1.96) | 0.11 (-0.16; 0.38) | 9
Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 500 mg/day, 52 weeks | HBV DNA < 5 log 10 copies/mL coupled with HBeAg loss or normalization of ALT levels | 52/52 | 26/41 34/44 | 63/77 | 0.82 (0.62; 1.09) | -0.14 (-0.33; 0.05) | -7
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks | At least one adverse event | 52/52 | 15/21 14/20 | 71/70 | 1.02 (0.69; 1.51) | 0.01 (-0.26; 0.29) | 70
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks | Influenza | 52/52 | 4/21 6/20 | 19/30 | 0.63 (0.21; 1.92) | -0.11 (-0.37; 0.15) | -9
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks | Headache | 52/52 | 4/21 2/20 | 19/10 | 1.90 (0.39; 9.28) | 0.09 (-0.12; 0.30) | 11
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks | Fatigue | 52/52 | 1/21 2/20 | 5/10 | 0.48 (0.05; 4.85) | -0.05 (-0.21; 0.11) | -19
Cough | 52/52 | 2/21 1/20 | 10/5 | 1.90 (0.19; 19.40) | 0.05 (-0.11; 0.20) | 22
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks | At least one adverse event | 52/52 | 15/21 14/20 | 71/70 | 1.02 (0.69; 1.51) | 0.01 (-0.26; 0.29) | 70
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks | Influenza | 52/52 | 4/21 6/20 | 19/30 | 0.63 (0.21; 1.92) | -0.11 (-0.37; 0.15) | -9
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks | Headache | 52/52 | 4/21 2/20 | 19/10 | 1.90 (0.39; 9.28) | 0.09 (-0.12; 0.30) | 11
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks | Fatigue | 52/52 | 1/21 2/20 | 5/10 | 0.48 (0.05; 4.85) | -0.05 (-0.21; 0.11) | -19
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks | Cough | 52/52 | 2/21 1/20 | 10/5 | 1.90 (0.19; 19.40) | 0.05 (-0.11; 0.20) | 22
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks | Pharyngolaryngeal pain | 52/52 | 0/21 3/20 | 0/15 | 0.14 (0.01; 2.48) | -0.15 (-0.32; 0.02) | -7
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks | Upper respiratory tract infection | 52/52 | 2/21 2/20 | 10/10 | 0.95 (0.15; 6.13) | 0.00 (-0.19; 0.18) | -210
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks | Nasopharyngitis | 52/52 | 2/21 1/20 | 10/5 | 1.90 (0.19; 19.40) | 0.05 (-0.11; 0.20) | 22
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Diarrhea | 52/52 | 1/21 1/20 | 5/5 | 0.95 (0.06; 14.22) | 0.00 (-0.13; 0.13) | -420
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Upper abdominal pain | 52/52 | 0/21 2/20 | 0/10 | 0.19 (0.01; 3.75) | -0.10 (-0.25; 0.05) | -10
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Back pain | 52/52 | 2/21 2/20 | 10/10 | 0.95 (0.15; 6.13) | 0.00 (-0.19; 0.18) | -210
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Dyspepsia | 52/52 | 0/21 0/20 | | | 0.00 (-0.09; 0.09)
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Dizziness | 52/52 | 1/21 2/20 | 5/10 | 0.48 (0.05; 4.85) | -0.05 (-0.21; 0.11) | -19
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Increased creatine phosphokinase level | 52/52 | 1/21 1/20 | 5/5 | 0.95 (0.06; 14.22) | 0.00 (-0.13; 0.13) | -420
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Nausea | 52/52 | 0/21 2/20 | 0/10 | 0.19 (0.01; 3.75) | -0.10 (-0.25; 0.05) | -10
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Depression | 52/52 | 1/21 1/20 | 5/5 | 0.95 (0.06; 14.22) | 0.00 (-0.13; 0.13) | -420
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day, 52 weeks | At least one adverse event | 52/52 | 15/21 13/19 | 71/68 | 1.04 (0.69; 1.57) | 0.03 (-0.25; 0.31) | 33
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day, 52 weeks
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day, 52 weeks | Influenza | 52/52 | 4/21 4/19 | 19/21 | 0.90 (0.26; 3.12) | -0.02 (-0.27; 0.23) | -50
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day, 52 weeks
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day, 52 weeks | Headache | 52/52 | 4/21 5/19 | 19/26 | 0.72 (0.23; 2.31) | -0.07 (-0.33; 0.19) | -14
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day, 52 weeks
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day, 52 weeks | Fatigue | 52/52 | 1/21 3/19 | 5/16 | 0.30 (0.03; 2.66) | -0.11 (-0.30; 0.08) | -9
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day, 52 weeks
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day, 52 weeks | Cough | 52/52 | 2/21 3/19 | 10/16 | 0.60 (0.11; 3.23) | -0.06 (-0.27; 0.14) | -16
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day, 52 weeks
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day, 52 weeks | Pharyngolaryngeal pain | 52/52 | 0/21 3/19 | 0/16 | 0.13 (0.01; 2.36) | -0.16 (-0.34; 0.02) | -6
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day, 52 weeks
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day, 52 weeks | Upper respiratory tract infection | 52/52 | 2/21 1/19 | 10/5 | 1.81 (0.18; 18.39) | 0.04 (-0.12; 0.20) | 23
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day, 52 weeks
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day, 52 weeks | Nasopharyngitis | 52/52 | 2/21 1/19 | 10/5 | 1.81 (0.18; 18.39) | 0.04 (-0.12; 0.20) | 23
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Diarrhea | 52/52 | 1/21 1/19 | 5/5 | 0.90 (0.06; 13.48) | -0.01 (-0.14; 0.13) | -200
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Upper abdominal pain | 52/52 | 0/21 1/19 | 0/5 | 0.30 (0.01; 7.02) | -0.05 (-0.18; 0.08) | -19
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Back pain | 52/52 | 2/21 0/19 | 10/0 | 4.55 (0.23; 89.08) | 0.10 (-0.05; 0.24) | 10
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Dyspepsia | 52/52 | 0/21 4/19 | 0/21 | 0.10 (0.01; 1.76) | -0.21 (-0.40; -0.02) | -5
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Dizziness | 52/52 | 1/21 1/19 | 5/5 | 0.90 (0.06; 13.48) | -0.01 (-0.14; 0.13) | -200
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Increased creatine phosphokinase level | 52/52 | 1/21 1/19 | 5/5 | 0.90 (0.06; 13.48) | -0.01 (-0.14; 0.13) | -200
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Nausea | 52/52 | 0/21 1/19 | 0/5 | 0.30 (0.01; 7.02) | -0.05 (-0.18; 0.08) | -19
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Depression | 52/52 | 1/21 2/19 | 5/11 | 0.45 (0.04; 4.60) | -0.06 (-0.22; 0.11) | -17
Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day, 52 weeks | At least one adverse event | 52/52 | 15/21 16/22 | 71/73 | 0.98 (0.68; 1.43) | -0.01 (-0.28; 0.26) | -77
Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day, 52 weeks
Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day, 52 weeks | Influenza | 52/52 | 4/21 4/22 | 19/18 | 1.05 (0.30; 3.66) | 0.01 (-0.22; 0.24) | 116
Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day, 52 weeks
Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day, 52 weeks | Headache | 52/52 | 4/21 1/22 | 19/5 | 4.19 (0.51; 34.50) | 0.15 (-0.04; 0.33) | 7
Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day, 52 weeks
Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day, 52 weeks | Fatigue | 52/52 | 1/21 1/22 | 5/5 | 1.05 (0.07; 15.69) | 0.00 (-0.12; 0.13) | 462
Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day, 52 weeks
Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day, 52 weeks | Cough | 52/52 | 2/21 2/22 | 10/9 | 1.05 (0.16; 6.77) | 0.00 (-0.17; 0.18) | 231
Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day, 52 weeks
Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day, 52 weeks | Pharyngolaryngeal pain | 52/52 | 0/21 2/22 | 0/9 | 0.21 (0.01; 4.11) | -0.09 (-0.23; 0.05) | -11
Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day, 52 weeks
Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day, 52 weeks | Upper respiratory tract infection | 52/52 | 2/21 3/22 | 10/14 | 0.70 (0.13; 3.77) | -0.04 (-0.23; 0.15) | -24
Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day, 52 weeks
Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day, 52 weeks | Nasopharyngitis | 52/52 | 2/21 1/22 | 10/5 | 2.10 (0.20; 21.42) | 0.05 (-0.10; 0.20) | 20
Diarrhea | 52/52 | 1/21 2/22 | 5/9 | 0.52 (0.05; 5.36) | -0.04 (-0.19; 0.11) | -23
Upper abdominal pain | 52/52 | 0/21 1/22 | 0/5 | 0.35 (0.01; 8.11) | -0.05 (-0.16; 0.07) | -22
Back pain | 52/52 | 2/21 0/22 | 10/0 | 5.23 (0.27; 102.87) | 0.10 (-0.05; 0.24) | 10
Dyspepsia | 52/52 | 0/21 0/22 | | | 0.00 (-0.09; 0.09)
Dizziness | 52/52 | 1/21 0/22 | 5/0 | 3.14 (0.13; 72.96) | 0.05 (-0.07; 0.17) | 21
Increased creatine phosphokinase level | 52/52 | 1/21 1/22 | 5/5 | 1.05 (0.07; 15.69) | 0.00 (-0.12; 0.13) | 462
Nausea | 52/52 | 0/21 1/22 | 0/5 | 0.35 (0.01; 8.11) | -0.05 (-0.16; 0.07) | -22
Depression | 52/52 | 1/21 0/22 | 5/0 | 3.14 (0.13; 72.96) | 0.05 (-0.07; 0.17) | 21
Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks | At least one adverse event | 52/52 | 15/21 15/22 | 71/68 | 1.05 (0.71; 1.55) | 0.03 (-0.24; 0.31) | 31
Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks
Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks | Influenza | 52/52 | 4/21 4/22 | 19/18 | 1.05 (0.30; 3.66) | 0.01 (-0.22; 0.24) | 116
Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks
Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks | Headache | 52/52 | 4/21 3/22 | 19/14 | 1.40 (0.35; 5.51) | 0.05 (-0.17; 0.27) | 18
Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks
Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks | Fatigue | 52/52 | 1/21 4/22 | 5/18 | 0.26 (0.03; 2.16) | -0.13 (-0.32; 0.05) | -7
Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks
Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks | Cough | 52/52 | 2/21 1/22 | 10/5 | 2.10 (0.20; 21.42) | 0.05 (-0.10; 0.20) | 20
Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks
Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks | Pharyngolaryngeal pain | 52/52 | 0/21 1/22 | 0/5 | 0.35 (0.01; 8.11) | -0.05 (-0.16; 0.07) | -22
Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks
Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks | Upper respiratory tract infection | 52/52 | 2/21 0/22 | 10/0 | 5.23 (0.27; 102.87) | 0.10 (-0.05; 0.24) | 10
Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks
Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks | Nasopharyngitis | 52/52 | 2/21 1/22 | 10/5 | 2.10 (0.20; 21.42) | 0.05 (-0.10; 0.20) | 20
Diarrhea | 52/52 | 1/21 1/22 | 5/5 | 1.05 (0.07; 15.69) | 0.00 (-0.12; 0.13) | 462
Upper abdominal pain | 52/52 | 0/21 2/22 | 0/9 | 0.21 (0.01; 4.11) | -0.09 (-0.23; 0.05) | -11
Back pain | 52/52 | 2/21 1/22 | 10/5 | 2.10 (0.20; 21.42) | 0.05 (-0.10; 0.20) | 20
Dyspepsia | 52/52 | 0/21 1/22 | 0/5 | 0.35 (0.01; 8.11) | -0.05 (-0.16; 0.07) | -22
Dizziness | 52/52 | 1/21 1/22 | 5/5 | 1.05 (0.07; 15.69) | 0.00 (-0.12; 0.13) | 462
Increased creatine phosphokinase level | 52/52 | 1/21 1/22 | 5/5 | 1.05 (0.07; 15.69) | 0.00 (-0.12; 0.13) | 462
Nausea | 52/52 | 0/21 1/22 | 0/5 | 0.35 (0.01; 8.11) | -0.05 (-0.16; 0.07) | -22
Depression | 52/52 | 1/21 0/22 | 5/0 | 3.14 (0.13; 72.96) | 0.05 (-0.07; 0.17) | 21
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day, 52 weeks | At least one adverse event | 52/52 | 14/20 13/19 | 70/68 | 1.02 (0.67; 1.56) | 0.02 (-0.27; 0.31) | 63
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day, 52 weeks
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day, 52 weeks | Influenza | 52/52 | 6/20 4/19 | 30/21 | 1.43 (0.48; 4.27) | 0.09 (-0.18; 0.36) | 11
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day, 52 weeks
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day, 52 weeks | Headache | 52/52 | 2/20 5/19 | 10/26 | 0.38 (0.08; 1.73) | -0.16 (-0.40; 0.07) | -6
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day, 52 weeks
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day, 52 weeks | Fatigue | 52/52 | 2/20 3/19 | 10/16 | 0.63 (0.12; 3.38) | -0.06 (-0.27; 0.15) | -17
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day, 52 weeks
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day, 52 weeks | Cough | 52/52 | 1/20 3/19 | 5/16 | 0.32 (0.04; 2.79) | -0.11 (-0.30; 0.08) | -9
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day, 52 weeks
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day, 52 weeks | Pharyngolaryngeal pain | 52/52 | 3/20 3/19 | 15/16 | 0.95 (0.22; 4.14) | -0.01 (-0.23; 0.22) | -127
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day, 52 weeks
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day, 52 weeks | Upper respiratory tract infection | 52/52 | 2/20 1/19 | 10/5 | 1.90 (0.19; 19.27) | 0.05 (-0.12; 0.21) | 21
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day, 52 weeks
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day, 52 weeks | Nasopharyngitis | 52/52 | 1/20 1/19 | 5/5 | 0.95 (0.06; 14.13) | 0.00 (-0.14; 0.14) | -380
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Diarrhea | 52/52 | 1/20 1/19 | 5/5 | 0.95 (0.06; 14.13) | 0.00 (-0.14; 0.14) | -380
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Upper abdominal pain | 52/52 | 2/20 1/19 | 10/5 | 1.90 (0.19; 19.27) | 0.05 (-0.12; 0.21) | 21
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Back pain | 52/52 | 2/20 0/19 | 10/0 | 4.76 (0.24; 93.19) | 0.10 (-0.05; 0.25) | 10
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Dyspepsia | 52/52 | 0/20 4/19 | 0/21 | 0.11 (0.01; 1.84) | -0.21 (-0.40; -0.02) | -5
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Dizziness | 52/52 | 2/20 1/19 | 10/5 | 1.90 (0.19; 19.27) | 0.05 (-0.12; 0.21) | 21
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Increased creatine phosphokinase level | 52/52 | 1/20 1/19 | 5/5 | 0.95 (0.06; 14.13) | 0.00 (-0.14; 0.14) | -380
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Nausea | 52/52 | 2/20 1/19 | 10/5 | 1.90 (0.19; 19.27) | 0.05 (-0.12; 0.21) | 21
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Depression | 52/52 | 1/20 2/19 | 5/11 | 0.48 (0.05; 4.82) | -0.06 (-0.22; 0.11) | -18
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day, 52 weeks | At least one adverse event | 52/52 | 14/20 16/22 | 70/73 | 0.96 (0.66; 1.41) | -0.03 (-0.30; 0.25) | -37
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day, 52 weeks
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day, 52 weeks | Influenza | 52/52 | 6/20 4/22 | 30/18 | 1.65 (0.54; 5.01) | 0.12 (-0.14; 0.38) | 8
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day, 52 weeks
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day, 52 weeks | Headache | 52/52 | 2/20 1/22 | 10/5 | 2.20 (0.22; 22.45) | 0.05 (-0.10; 0.21) | 18
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day, 52 weeks
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day, 52 weeks | Fatigue | 52/52 | 2/20 1/22 | 10/5 | 2.20 (0.22; 22.45) | 0.05 (-0.10; 0.21) | 18
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day, 52 weeks
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day, 52 weeks | Cough | 52/52 | 1/20 2/22 | 5/9 | 0.55 (0.05; 5.61) | -0.04 (-0.19; 0.11) | -24
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day, 52 weeks
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day, 52 weeks | Pharyngolaryngeal pain | 52/52 | 3/20 2/22 | 15/9 | 1.65 (0.31; 8.89) | 0.06 (-0.14; 0.26) | 17
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day, 52 weeks
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day, 52 weeks | Upper respiratory tract infection | 52/52 | 2/20 3/22 | 10/14 | 0.73 (0.14; 3.95) | -0.04 (-0.23; 0.16) | -28
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day, 52 weeks
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day, 52 weeks | Nasopharyngitis | 52/52 | 1/20 1/22 | 5/5 | 1.10 (0.07; 16.45) | 0.00 (-0.12; 0.13) | 220
Diarrhea | 52/52 | 1/20 2/22 | 5/9 | 0.55 (0.05; 5.61) | -0.04 (-0.19; 0.11) | -24
Upper abdominal pain | 52/52 | 2/20 1/22 | 10/5 | 2.20 (0.22; 22.45) | 0.05 (-0.10; 0.21) | 18
Back pain | 52/52 | 2/20 0/22 | 10/0 | 5.48 (0.28; 107.62) | 0.10 (-0.05; 0.25) | 10
Dyspepsia | 52/52 | 0/20 0/22 | | | 0.00 (-0.09; 0.09)
Dizziness | 52/52 | 2/20 0/22 | 10/0 | 5.48 (0.28; 107.62) | 0.10 (-0.05; 0.25) | 10
Increased creatine phosphokinase level | 52/52 | 1/20 1/22 | 5/5 | 1.10 (0.07; 16.45) | 0.00 (-0.12; 0.13) | 220
Nausea | 52/52 | 2/20 1/22 | 10/5 | 2.20 (0.22; 22.45) | 0.05 (-0.10; 0.21) | 18
Depression | 52/52 | 1/20 0/22 | 5/0 | 3.29 (0.14; 76.33) | 0.05 (-0.08; 0.18) | 20
Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks | At least one adverse event | 52/52 | 14/20 15/22 | 70/68 | 1.03 (0.68; 1.54) | 0.02 (-0.26; 0.30) | 55
Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks
Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks | Influenza | 52/52 | 6/20 4/22 | 30/18 | 1.65 (0.54; 5.01) | 0.12 (-0.14; 0.38) | 8
Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks
Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks | Headache | 52/52 | 2/20 3/22 | 10/14 | 0.73 (0.14; 3.95) | -0.04 (-0.23; 0.16) | -28
Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks
Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks | Fatigue | 52/52 | 2/20 4/22 | 10/18 | 0.55 (0.11; 2.69) | -0.08 (-0.29; 0.13) | -12
Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks
Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks | Cough | 52/52 | 1/20 1/22 | 5/5 | 1.10 (0.07; 16.45) | 0.00 (-0.12; 0.13) | 220
Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks
Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks | Pharyngolaryngeal pain | 52/52 | 3/20 1/22 | 15/5 | 3.30 (0.37; 29.21) | 0.10 (-0.07; 0.28) | 10
Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks
Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks | Upper respiratory tract infection | 52/52 | 2/20 0/22 | 10/0 | 5.48 (0.28; 107.62) | 0.10 (-0.05; 0.25) | 10
Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks
Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks | Nasopharyngitis | 52/52 | 1/20 1/22 | 5/5 | 1.10 (0.07; 16.45) | 0.00 (-0.12; 0.13) | 220
Diarrhea | 52/52 | 1/20 1/22 | 5/5 | 1.10 (0.07; 16.45) | 0.00 (-0.12; 0.13) | 220
Upper abdominal pain | 52/52 | 2/20 2/22 | 10/9 | 1.10 (0.17; 7.09) | 0.01 (-0.17; 0.19) | 110
Back pain | 52/52 | 2/20 1/22 | 10/5 | 2.20 (0.22; 22.45) | 0.05 (-0.10; 0.21) | 18
Dyspepsia | 52/52 | 0/20 1/22 | 0/5 | 0.37 (0.02; 8.48) | -0.05 (-0.17; 0.07) | -22
Dizziness | 52/52 | 2/20 1/22 | 10/5 | 2.20 (0.22; 22.45) | 0.05 (-0.10; 0.21) | 18
Increased creatine phosphokinase level | 52/52 | 1/20 1/22 | 5/5 | 1.10 (0.07; 16.45) | 0.00 (-0.12; 0.13) | 220
Nausea | 52/52 | 2/20 1/22 | 10/5 | 2.20 (0.22; 22.45) | 0.05 (-0.10; 0.21) | 18
Depression | 52/52 | 1/20 0/22 | 5/0 | 3.29 (0.14; 76.33) | 0.05 (-0.08; 0.18) | 20
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day + Placebo, 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks | At least one adverse event | 52/52 | 16/22 15/22 | 73/68 | 1.07 (0.73; 1.57) | 0.05 (-0.22; 0.31) | 22
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day + Placebo, 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day + Placebo, 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks | Influenza | 52/52 | 4/22 4/22 | 18/18 | 1.00 (0.29; 3.50) | 0.00 (-0.23; 0.23)
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day + Placebo, 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day + Placebo, 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks | Headache | 52/52 | 1/22 3/22 | 5/14 | 0.33 (0.04; 2.96) | -0.09 (-0.26; 0.08) | -11
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day + Placebo, 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day + Placebo, 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks | Fatigue | 52/52 | 1/22 4/22 | 5/18 | 0.25 (0.03; 2.06) | -0.14 (-0.32; 0.05) | -7
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day + Placebo, 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day + Placebo, 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks | Cough | 52/52 | 2/22 1/22 | 9/5 | 2.00 (0.20; 20.49) | 0.05 (-0.10; 0.19) | 22
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day + Placebo, 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day + Placebo, 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks | Pharyngolaryngeal pain | 52/52 | 2/22 1/22 | 9/5 | 2.00 (0.20; 20.49) | 0.05 (-0.10; 0.19) | 22
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day + Placebo, 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day + Placebo, 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks | Upper respiratory tract infection | 52/52 | 3/22 0/22 | 14/0 | 7.00 (0.38; 128.02) | 0.14 (-0.02; 0.29) | 7
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day + Placebo, 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 400 mg/day + Placebo, 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 600 mg/day, 52 weeks | Nasopharyngitis | 52/52 | 1/22 1/22 | 5/5 | 1.00 (0.07; 15.00) | 0.00 (-0.12; 0.12)
Diarrhea | 52/52 | 2/22 1/22 | 9/5 | 2.00 (0.20; 20.49) | 0.05 (-0.10; 0.19) | 22
Upper abdominal pain | 52/52 | 1/22 2/22 | 5/9 | 0.50 (0.05; 5.12) | -0.05 (-0.19; 0.10) | -22
Back pain | 52/52 | 0/22 1/22 | 0/5 | 0.33 (0.01; 7.76) | -0.05 (-0.16; 0.07) | -22
Dyspepsia | 52/52 | 0/22 1/22 | 0/5 | 0.33 (0.01; 7.76) | -0.05 (-0.16; 0.07) | -22
Dizziness | 52/52 | 0/22 1/22 | 0/5 | 0.33 (0.01; 7.76) | -0.05 (-0.16; 0.07) | -22
Increased creatine phosphokinase level | 52/52 | 1/22 1/22 | 5/5 | 1.00 (0.07; 15.00) | 0.00 (-0.12; 0.12)
Nausea | 52/52 | 1/22 1/22 | 5/5 | 1.00 (0.07; 15.00) | 0.00 (-0.12; 0.12)
Depression | 52/52 | 0/22 0/22 | | | 0.00 (-0.08; 0.08)
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 500 mg/day (both 400mg or 600 mg/day) lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day, 52 weeks | Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day, 52 weeks | HBV DNA PCR non detectable | 52/52 | 20/41 6/19 | 49/32 | 1.54 (0.74; 3.21) | 0.17 (-0.09; 0.43) | 6
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 500 mg/day (both 400mg or 600 mg/day) lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day, 52 weeks | Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day, 52 weeks
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 500 mg/day (both 400mg or 600 mg/day) lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day, 52 weeks | Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day, 52 weeks | HBeAg loss | 52/52 | 7/41 5/19 | 17/28 | 0.65 (0.24; 1.78) | -0.09 (-0.32; 0.14) | -11
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 500 mg/day (both 400mg or 600 mg/day) lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day, 52 weeks | Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day, 52 weeks
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 500 mg/day (both 400mg or 600 mg/day) lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day, 52 weeks | HBeAg seroconversion | 52/52 | 6/41 4/19 | 15/22 | 0.70 (0.22; 2.18) | -0.06 (-0.28; 0.15) | -16
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 500 mg/day (both 400mg or 600 mg/day) lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day, 52 weeks
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 500 mg/day (both 400mg or 600 mg/day) lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day, 52 weeks | HBeAg loss and HBV DNA <5 log10 copies/mL | 52/52 | 8/41 5/19 | 20/26 | 0.74 (0.28; 1.97) | -0.07 (-0.30; 0.16) | -15
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 500 mg/day (both 400mg or 600 mg/day) lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day, 52 weeks
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 500 mg/day (both 400mg or 600 mg/day) lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day, 52 weeks | Virologic break through on treatment increase in HBV DNA levels to >5 log10 copies/mL | 52/52 | 5/41 3/19 | 12/16 | 0.77 (0.21; 2.90) | -0.04 (-0.23; 0.16) | -28
Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 500 mg/day, 52 weeks | HBV DNA PCR non detectable | 52/52 | 20/41 27/44 | 49/61 | 0.79 (0.54; 1.18) | -0.13 (-0.34; 0.08) | -8
Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 500 mg/day, 52 weeks
Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 500 mg/day, 52 weeks | HBeAg loss | 52/52 | 7/41 15/44 | 17/33 | 0.50 (0.23; 1.10) | -0.17 (-0.35; 0.01) | -6
Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 500 mg/day, 52 weeks
HBeAg seroconversion | 52/52 | 6/41 14/44 | 15/31 | 0.46 (0.20; 1.08) | -0.17 (-0.35; 0.00) | -6
HBeAg loss and HBV DNA <5 log10 copies/mL | 52/52 | 8/41 14/44 | 20/32 | 0.61 (0.29; 1.31) | -0.12 (-0.31; 0.06) | -8
Virologic breakthrough on treatment increase in HBV DNA levels to >5 log10 copies/mL | 52/52 | 5/41 2/44 | 12/5 | 2.68 (0.55; 13.07) | 0.08 (-0.04; 0.19) | 13
Lai, 2007^71^ Telbivudine (Idenix Pharmaceuticals Inc Cambridge, MA), 600 mg/day, 52 weeks | Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day, 52 weeks | Discontinuation due to adverse events, clinical disease progression, or lack of efficacy | 52/52 | 2/680 8/687 | 0/1 | 0.25 (0.05; 1.19) | -0.01 (-0.02; 0.00) | -115
Lai, 2007^71^ Telbivudine (Idenix Pharmaceuticals Inc Cambridge, MA), 600 mg/day, 52 weeks | Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day, 52 weeks
Lai, 2007^71^ Telbivudine (Idenix Pharmaceuticals Inc Cambridge, MA), 600 mg/day, 52 weeks | Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day, 52 weeks | Any adverse event | 52/52 | 496/680 474/687 | 73/69 | 1.06 (0.99; 1.13) | 0.04 (-0.01; 0.09) | 25
Lai, 2007^71^ Telbivudine (Idenix Pharmaceuticals Inc Cambridge, MA), 600 mg/day, 52 weeks | Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day, 52 weeks
Lai, 2007^71^ Telbivudine (Idenix Pharmaceuticals Inc Cambridge, MA), 600 mg/day, 52 weeks | Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day, 52 weeks | Upper respiratory tract infection | 52/52 | 82/680 82/687 | 12/12 | 1.01 (0.76; 1.35) | 0.00 (-0.03; 0.04) | 814
Lai, 2007^71^ Telbivudine (Idenix Pharmaceuticals Inc Cambridge, MA), 600 mg/day, 52 weeks | Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day, 52 weeks
Lai, 2007^71^ Telbivudine (Idenix Pharmaceuticals Inc Cambridge, MA), 600 mg/day, 52 weeks | Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day, 52 weeks | Headache | 52/52 | 68/680 82/687 | 10/12 | 0.84 (0.62; 1.13) | -0.02 (-0.05; 0.01) | -52
Lai, 2007^71^ Telbivudine (Idenix Pharmaceuticals Inc Cambridge, MA), 600 mg/day, 52 weeks | Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day, 52 weeks
Lai, 2007^71^ Telbivudine (Idenix Pharmaceuticals Inc Cambridge, MA), 600 mg/day, 52 weeks | Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day, 52 weeks | Nasopharyngitis | 52/52 | 68/680 69/687 | 10/10 | 1.00 (0.72; 1.37) | 0.00 (-0.03; 0.03) | -2290
Lai, 2007^71^ Telbivudine (Idenix Pharmaceuticals Inc Cambridge, MA), 600 mg/day, 52 weeks | Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day, 52 weeks
Lai, 2007^71^ Telbivudine (Idenix Pharmaceuticals Inc Cambridge, MA), 600 mg/day, 52 weeks | Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day, 52 weeks | Fatigue | 52/52 | 68/680 62/687 | 10/9 | 1.11 (0.80; 1.54) | 0.01 (-0.02; 0.04) | 103
Lai, 2007^71^ Telbivudine (Idenix Pharmaceuticals Inc Cambridge, MA), 600 mg/day, 52 weeks | Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day, 52 weeks
Lai, 2007^71^ Telbivudine (Idenix Pharmaceuticals Inc Cambridge, MA), 600 mg/day, 52 weeks | Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day, 52 weeks | Increased blood creatine kinase | 52/52 | 54/680 41/687 | 8/6 | 1.33 (0.90; 1.97) | 0.02 (-0.01; 0.05) | 51
Lai, 2007^71^ Telbivudine (Idenix Pharmaceuticals Inc Cambridge, MA), 600 mg/day, 52 weeks | Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day, 52 weeks
Lai, 2007^71^ Telbivudine (Idenix Pharmaceuticals Inc Cambridge, MA), 600 mg/day, 52 weeks | Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day, 52 weeks | Post procedure pain | 52/52 | 41/680 34/687 | 6/5 | 1.22 (0.78; 1.90) | 0.01 (-0.01; 0.03) | 93
Lai, 2007^71^ Telbivudine (Idenix Pharmaceuticals Inc Cambridge, MA), 600 mg/day, 52 weeks | Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day, 52 weeks
Lai, 2007^71^ Telbivudine (Idenix Pharmaceuticals Inc Cambridge, MA), 600 mg/day, 52 weeks | Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day, 52 weeks | Cough | 52/52 | 41/680 41/687 | 6/6 | 1.01 (0.66; 1.54) | 0.00 (-0.02; 0.03) | 1628
Lai, 2007^71^ Telbivudine (Idenix Pharmaceuticals Inc Cambridge, MA), 600 mg/day, 52 weeks | Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day, 52 weeks
Lai, 2007^71^ Telbivudine (Idenix Pharmaceuticals Inc Cambridge, MA), 600 mg/day, 52 weeks | Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day, 52 weeks | Upper abdominal pain | 52/52 | 34/680 48/687 | 5/7 | 0.72 (0.47; 1.10) | -0.02 (-0.05; 0.01) | -50
Lai, 2007^71^ Telbivudine (Idenix Pharmaceuticals Inc Cambridge, MA), 600 mg/day, 52 weeks | Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day, 52 weeks
Lai, 2007^71^ Telbivudine (Idenix Pharmaceuticals Inc Cambridge, MA), 600 mg/day, 52 weeks | Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day, 52 weeks | Influenza | 52/52 | 34/680 34/687 | 5/5 | 1.01 (0.64; 1.61) | 0.00 (-0.02; 0.02) | 1963
Lai, 2007^71^ Telbivudine (Idenix Pharmaceuticals Inc Cambridge, MA), 600 mg/day, 52 weeks | Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day, 52 weeks
Diarrhea | 52/52 | 34/680 27/687 | 5/4 | 1.27 (0.78; 2.08) | 0.01 (-0.01; 0.03) | 93
Nausea | 52/52 | 34/680 27/687 | 5/4 | 1.27 (0.78; 2.08) | 0.01 (-0.01; 0.03) | 93
Dizziness | 52/52 | 27/680 34/687 | 4/5 | 0.80 (0.49; 1.31) | -0.01 (-0.03; 0.01) | -102
Dyspepsia | 52/52 | 14/680 34/687 | 2/5 | 0.42 (0.23; 0.77) | -0.03 (-0.05; -0.01) | -35
Grade 3 or 4 laboratory abnormalities in ALT | 52/52 | 25/680 43/687 | 4/6 | 0.59 (0.36; 0.95) | -0.03 (-0.05; 0.00) | -39
Grade 3 or 4 laboratory abnormalities in AST | 52/52 | 18/680 32/687 | 3/5 | 0.57 (0.32; 1.00) | -0.02 (-0.04; 0.00) | -50
Grade 3 or 4 laboratory abnormalities in creatine kinase | 52/52 | 51/680 21/687 | 8/3 | 2.45 (1.49; 4.03) | 0.04 (0.02; 0.07) | 23
Grade 3 or 4 laboratory abnormalities in Lipase | 52/52 | 12/680 22/687 | 2/3 | 0.55 (0.27; 1.10) | -0.01 (-0.03; 0.00) | -70
Grade 3 or 4 laboratory abnormalities in amylase | 52/52 | 1/680 2/687 | | 0.51 (0.05; 5.56) | 0.00 (-0.01; 0.00) | -694
Grade 3 or 4 laboratory abnormalities in absolute neutrophil count | 52/52 | 13/680 9/687 | 2/1 | 1.46 (0.63; 3.39) | 0.01 (-0.01; 0.02) | 166
Grade 3 or 4 laboratory abnormalities in platelet count | 52/52 | 5/680 4/687 | 1/1 | 1.26 (0.34; 4.68) | 0.00 (-0.01; 0.01) | 653
Grade 3 or 4 laboratory abnormalities in total bilirubin | 52/52 | 0/680 2/687 | | 0.20 (0.01; 4.20) | 0.00 (-0.01; 0.00) | -344
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 24 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 24 weeks | ALT normalization | 24/24 | 26/45 56/91 | 58/61 | 0.94 (0.70; 1.26) | -0.04 (-0.21; 0.14) | -27
Adjusted for baseline covariates (baseline HBV DNA level, age, body mass index, sex, and study site) odds ratio of ALT normalization | 24/24 | 0/45 0/91 | | 1.81 (0.56; 5.85)
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks | Serum ALT normalization | 52/52 | 36/45 38/45 | 79/85 | 0.95 (0.78; 1.15) | -0.04 (-0.20; 0.11) | -23
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 52 weeks
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, CA) for 24 weeks and then telbivudine(Idenix Pharmaceuticals, Cambridge, MA) for the remaining 28 weeks, 10 mg/day, 52 weeks | Serum ALT normalization | 52/52 | 36/45 39/46 | 79/85 | 0.94 (0.78; 1.14) | -0.05 (-0.20; 0.11) | -21
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 52 weeks
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks | Adjusted for baseline covariates (baseline HBV DNA level, age, body mass index, sex, and study site) odds ratio of serum ALT normalization | 52/52 | 0/45 0/45 | | 0.61 (0.18; 2.08)
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks | Total adverse effects | 52/52 | 34/45 27/45 | 76/61 | 1.26 (0.94; 1.68) | 0.16 (-0.03; 0.35) | 6
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks | Upper respiratory tract infection | 52/52 | 5/45 5/45 | 11/11 | 1.00 (0.31; 3.22) | 0.00 (-0.13; 0.13)
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks | Headache | 52/52 | 5/45 3/45 | 11/7 | 1.67 (0.42; 6.56) | 0.04 (-0.07; 0.16) | 23
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks | Back pain | 52/52 | 6/45 3/45 | 13/7 | 2.00 (0.53; 7.51) | 0.07 (-0.06; 0.19) | 15
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks | Diarrhea | 52/52 | 6/45 1/45 | 13/2 | 6.00 (0.75; 47.85) | 0.11 (0.00; 0.22) | 9
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks | Influenza | 52/52 | 5/45 3/45 | 11/7 | 1.67 (0.42; 6.56) | 0.04 (-0.07; 0.16) | 23
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks | Upper abdominal pain | 52/52 | 3/45 2/45 | 7/5 | 1.50 (0.26; 8.55) | 0.02 (-0.07; 0.12) | 45
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks | Nasopharyngitis | 52/52 | 1/45 5/45 | 2/11 | 0.20 (0.02; 1.64) | -0.09 (-0.19; 0.01) | -11
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks | Cough | 52/52 | 1/45 0/45 | 2/0 | 3.00 (0.13; 71.74) | 0.02 (-0.04; 0.08) | 45
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks | Arthralgia | 52/52 | 2/45 2/45 | 4/5 | 1.00 (0.15; 6.79) | 0.00 (-0.09; 0.09)
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks | Fatigue | 52/52 | 2/45 0/45 | 4/0 | 5.00 (0.25; 101.31) | 0.04 (-0.03; 0.12) | 23
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks | Dizziness | 52/52 | 1/45 0/45 | 2/0 | 3.00 (0.13; 71.74) | 0.02 (-0.04; 0.08) | 45
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 52 weeks
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 52 weeks | Malaise | 52/52 | 3/45 0/45 | 7/0 | 7.00 (0.37; 131.73) | 0.07 (-0.02; 0.15) | 15
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 52 weeks
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 52 weeks | Nausea | 52/52 | 2/45 2/45 | 4/5 | 1.00 (0.15; 6.79) | 0.00 (-0.09; 0.09)
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 52 weeks
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 52 weeks | Pharyngolaryngeal pain | 52/52 | 1/45 3/45 | 2/7 | 0.33 (0.04; 3.08) | -0.04 (-0.13; 0.04) | -23
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 52 weeks
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 52 weeks | Abdominal pain | 52/52 | 2/45 1/45 | 4/2 | 2.00 (0.19; 21.28) | 0.02 (-0.05; 0.10) | 45
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 52 weeks
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 52 weeks | Epigastric discomfort | 52/52 | 2/45 0/45 | 4/0 | 5.00 (0.25; 101.31) | 0.04 (-0.03; 0.12) | 23
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 52 weeks
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 52 weeks | Gastritis | 52/52 | 3/45 0/45 | 7/0 | 7.00 (0.37; 131.73) | 0.07 (-0.02; 0.15) | 15
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 52 weeks
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 52 weeks | Hepatic steatosis | 52/52 | 2/45 1/45 | 4/2 | 2.00 (0.19; 21.28) | 0.02 (-0.05; 0.10) | 45
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 52 weeks
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 52 weeks | Mouth ulceration | 52/52 | 0/45 2/45 | 0/5 | 0.20 (0.01; 4.05) | -0.04 (-0.12; 0.03) | -23
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 52 weeks
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 52 weeks | Myalgia | 52/52 | 1/45 0/45 | 2/0 | 3.00 (0.13; 71.74) | 0.02 (-0.04; 0.08) | 45
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 52 weeks
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 52 weeks | Toothache | 52/52 | 2/45 1/45 | 4/2 | 2.00 (0.19; 21.28) | 0.02 (-0.05; 0.10) | 45
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 52 weeks
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 52 weeks | Hepatitis B | 52/52 | 0/45 2/45 | 0/5 | 0.20 (0.01; 4.05) | -0.04 (-0.12; 0.03) | -23
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 52 weeks
Hordeolum | 52/52 | 2/45 0/45 | 4/0 | 5.00 (0.25; 101.31) | 0.04 (-0.03; 0.12) | 23
Allergic rhinitis | 52/52 | 0/45 2/45 | 0/5 | 0.20 (0.01; 4.05) | -0.04 (-0.12; 0.03) | -23
Adefovir (Hepsera, Gilead Sciences, Foster City, CA) for 24 weeks and then telbivudine(Idenix Pharmaceuticals, Cambridge, MA) for the remaining 28 weeks, 10 mg/day, 52 weeks | Total adverse effects | 52/52 | 34/45 31/46 | 76/67 | 1.12 (0.86; 1.46) | 0.08 (-0.10; 0.27) | 12
Adefovir (Hepsera, Gilead Sciences, Foster City, CA) for 24 weeks and then telbivudine(Idenix Pharmaceuticals, Cambridge, MA) for the remaining 28 weeks, 10 mg/day, 52 weeks
Adefovir (Hepsera, Gilead Sciences, Foster City, CA) for 24 weeks and then telbivudine(Idenix Pharmaceuticals, Cambridge, MA) for the remaining 28 weeks, 10 mg/day, 52 weeks | Upper respiratory tract infection | 52/52 | 5/45 6/46 | 11/13 | 0.85 (0.28; 2.59) | -0.02 (-0.15; 0.11) | -52
Adefovir (Hepsera, Gilead Sciences, Foster City, CA) for 24 weeks and then telbivudine(Idenix Pharmaceuticals, Cambridge, MA) for the remaining 28 weeks, 10 mg/day, 52 weeks
Adefovir (Hepsera, Gilead Sciences, Foster City, CA) for 24 weeks and then telbivudine(Idenix Pharmaceuticals, Cambridge, MA) for the remaining 28 weeks, 10 mg/day, 52 weeks | Headache | 52/52 | 5/45 6/46 | 11/13 | 0.85 (0.28; 2.59) | -0.02 (-0.15; 0.11) | -52
Adefovir (Hepsera, Gilead Sciences, Foster City, CA) for 24 weeks and then telbivudine(Idenix Pharmaceuticals, Cambridge, MA) for the remaining 28 weeks, 10 mg/day, 52 weeks
Adefovir (Hepsera, Gilead Sciences, Foster City, CA) for 24 weeks and then telbivudine(Idenix Pharmaceuticals, Cambridge, MA) for the remaining 28 weeks, 10 mg/day, 52 weeks | Back pain | 52/52 | 6/45 3/46 | 13/7 | 2.04 (0.54; 7.68) | 0.07 (-0.05; 0.19) | 15
Adefovir (Hepsera, Gilead Sciences, Foster City, CA) for 24 weeks and then telbivudine(Idenix Pharmaceuticals, Cambridge, MA) for the remaining 28 weeks, 10 mg/day, 52 weeks
Adefovir (Hepsera, Gilead Sciences, Foster City, CA) for 24 weeks and then telbivudine(Idenix Pharmaceuticals, Cambridge, MA) for the remaining 28 weeks, 10 mg/day, 52 weeks | Diarrhea | 52/52 | 6/45 5/46 | 13/11 | 1.23 (0.40; 3.73) | 0.02 (-0.11; 0.16) | 41
Adefovir (Hepsera, Gilead Sciences, Foster City, CA) for 24 weeks and then telbivudine(Idenix Pharmaceuticals, Cambridge, MA) for the remaining 28 weeks, 10 mg/day, 52 weeks
Adefovir (Hepsera, Gilead Sciences, Foster City, CA) for 24 weeks and then telbivudine(Idenix Pharmaceuticals, Cambridge, MA) for the remaining 28 weeks, 10 mg/day, 52 weeks | Influenza | 52/52 | 5/45 4/46 | 11/9 | 1.28 (0.37; 4.46) | 0.02 (-0.10; 0.15) | 41
Adefovir (Hepsera, Gilead Sciences, Foster City, CA) for 24 weeks and then telbivudine(Idenix Pharmaceuticals, Cambridge, MA) for the remaining 28 weeks, 10 mg/day, 52 weeks
Adefovir (Hepsera, Gilead Sciences, Foster City, CA) for 24 weeks and then telbivudine(Idenix Pharmaceuticals, Cambridge, MA) for the remaining 28 weeks, 10 mg/day, 52 weeks | Upper abdominal pain | 52/52 | 3/45 5/46 | 7/11 | 0.61 (0.16; 2.42) | -0.04 (-0.16; 0.07) | -24
Adefovir (Hepsera, Gilead Sciences, Foster City, CA) for 24 weeks and then telbivudine(Idenix Pharmaceuticals, Cambridge, MA) for the remaining 28 weeks, 10 mg/day, 52 weeks
Adefovir (Hepsera, Gilead Sciences, Foster City, CA) for 24 weeks and then telbivudine(Idenix Pharmaceuticals, Cambridge, MA) for the remaining 28 weeks, 10 mg/day, 52 weeks | Nasopharyngitis | 52/52 | 1/45 2/46 | 2/4 | 0.51 (0.05; 5.44) | -0.02 (-0.09; 0.05) | -47
Adefovir (Hepsera, Gilead Sciences, Foster City, CA) for 24 weeks and then telbivudine(Idenix Pharmaceuticals, Cambridge, MA) for the remaining 28 weeks, 10 mg/day, 52 weeks
Adefovir (Hepsera, Gilead Sciences, Foster City, CA) for 24 weeks and then telbivudine(Idenix Pharmaceuticals, Cambridge, MA) for the remaining 28 weeks, 10 mg/day, 52 weeks | Cough | 52/52 | 1/45 6/46 | 2/13 | 0.17 (0.02; 1.36) | -0.11 (-0.21; 0.00) | -9
Adefovir (Hepsera, Gilead Sciences, Foster City, CA) for 24 weeks and then telbivudine(Idenix Pharmaceuticals, Cambridge, MA) for the remaining 28 weeks, 10 mg/day, 52 weeks
Adefovir (Hepsera, Gilead Sciences, Foster City, CA) for 24 weeks and then telbivudine(Idenix Pharmaceuticals, Cambridge, MA) for the remaining 28 weeks, 10 mg/day, 52 weeks | Arthralgia | 52/52 | 2/45 2/46 | 4/4 | 1.02 (0.15; 6.95) | 0.00 (-0.08; 0.09) | 1035
Adefovir (Hepsera, Gilead Sciences, Foster City, CA) for 24 weeks and then telbivudine(Idenix Pharmaceuticals, Cambridge, MA) for the remaining 28 weeks, 10 mg/day, 52 weeks
Adefovir (Hepsera, Gilead Sciences, Foster City, CA) for 24 weeks and then telbivudine(Idenix Pharmaceuticals, Cambridge, MA) for the remaining 28 weeks, 10 mg/day, 52 weeks | Fatigue | 52/52 | 2/45 4/46 | 4/9 | 0.51 (0.10; 2.65) | -0.04 (-0.14; 0.06) | -24
Adefovir (Hepsera, Gilead Sciences, Foster City, CA) for 24 weeks and then telbivudine(Idenix Pharmaceuticals, Cambridge, MA) for the remaining 28 weeks, 10 mg/day, 52 weeks
Adefovir (Hepsera, Gilead Sciences, Foster City, CA) for 24 weeks and then telbivudine(Idenix Pharmaceuticals, Cambridge, MA) for the remaining 28 weeks, 10 mg/day, 52 weeks | Dizziness | 52/52 | 1/45 4/46 | 2/9 | 0.26 (0.03; 2.20) | -0.06 (-0.16; 0.03) | -15
Adefovir (Hepsera, Gilead Sciences, Foster City, CA) for 24 weeks and then telbivudine(Idenix Pharmaceuticals, Cambridge, MA) for the remaining 28 weeks, 10 mg/day, 52 weeks
Malaise | 52/52 | 3/45 2/46 | 7/4 | 1.53 (0.27; 8.75) | 0.02 (-0.07; 0.12) | 43
Nausea | 52/52 | 2/45 1/46 | 4/2 | 2.04 (0.19; 21.76) | 0.02 (-0.05; 0.10) | 44
Pharyngolaryngeal pain | 52/52 | 1/45 1/46 | 2/2 | 1.02 (0.07; 15.85) | 0.00 (-0.06; 0.06) | 2070
Abdominal pain | 52/52 | 2/45 0/46 | 4/0 | 5.11 (0.25; 103.54) | 0.04 (-0.03; 0.12) | 23
Epigastric discomfort | 52/52 | 2/45 1/46 | 4/2 | 2.04 (0.19; 21.76) | 0.02 (-0.05; 0.10) | 44
Gastritis | 52/52 | 3/45 0/46 | 7/0 | 7.15 (0.38; 134.64) | 0.07 (-0.02; 0.15) | 15
Hepatic steatosis | 52/52 | 2/45 0/46 | 4/0 | 5.11 (0.25; 103.54) | 0.04 (-0.03; 0.12) | 23
Mouth ulceration | 52/52 | 0/45 1/46 | 0/2 | 0.34 (0.01; 8.15) | -0.02 (-0.08; 0.04) | -46
Myalgia | 52/52 | 1/45 2/46 | 2/4 | 0.51 (0.05; 5.44) | -0.02 (-0.09; 0.05) | -47
Toothache | 52/52 | 2/45 0/46 | 4/0 | 5.11 (0.25; 103.54) | 0.04 (-0.03; 0.12) | 23
Hepatitis B | 52/52 | 0/45 0/46 | | | 0.00 (-0.04; 0.04)
Hordeolum | 52/52 | 2/45 0/46 | 4/0 | 5.11 (0.25; 103.54) | 0.04 (-0.03; 0.12) | 23
Allergic rhinitis | 52/52 | 0/45 0/46 | | | 0.00 (-0.04; 0.04)
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 24 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 24 weeks | HBV DNA PCR-negative | 24/24 | 18/45 11/91 | 39/12 | 3.31 (1.71; 6.40) | 0.28 (0.12; 0.44) | 4
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 24 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 24 weeks
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 24 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 24 weeks | HBeAg loss | 24/24 | 7/45 10/91 | 16/11 | 1.42 (0.58; 3.47) | 0.05 (-0.08; 0.17) | 22
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 24 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 24 weeks
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 24 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 24 weeks | Adjusted for baseline covariates (baseline HBV DNA level, age, body mass index, sex, and study site), OR of HBeAg seroconversion | 24/24 | 7/45 9/91 | 16/10 | 6.03 (2.20; 16.52) | 0.06 (-0.07; 0.18) | 18
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 24 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 24 weeks
Adjusted for baseline covariates odds ratio of HBV DNA PCR-negative | 24/24 | 0/45 0/91 | | 0.07 (0.02; 0.29)
Adjusted for baseline covariates odds ratio of HBV DNA <5 log10 copies/mL | 24/24 | 0/45 0/91 | | 0.91 (0.41; 2.04)
Adjusted for baseline covariates odds ratio of HBeAg loss | 24/24 | 0/45 0/91 | | 2.30 (0.69; 7.70)
HBV DNA PCR-negative | 52/52 | 27/45 18/45 | 60/40 | 1.50 (0.98; 2.31) | 0.20 (0.00; 0.40) | 5
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks | HBeAg loss | 52/52 | 14/45 9/45 | 30/21 | 1.52 (0.73; 3.16) | 0.10 (-0.07; 0.28) | 10
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks | HBeAg seroconversion | 52/52 | 13/45 9/45 | 28/19 | 1.44 (0.69; 3.04) | 0.09 (-0.09; 0.27) | 11
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 52 weeks | Primary treatment failure | 52/52 | 1/45 13/45 | 2/29 | 0.08 (0.01; 0.56) | -0.27 (-0.41; -0.13) | -4
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 52 weeks
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 52 weeks | HBV DNA PCR-negative | 52/52 | 27/45 25/46 | 60/54 | 1.10 (0.77; 1.58) | 0.06 (-0.15; 0.26) | 18
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 52 weeks
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, CA) for 24 weeks and then telbivudine (Idenix Pharmaceuticals, Cambridge, MA) for the remaining 28 weeks, 10 mg/day, 52 weeks | HBeAg loss | 52/52 | 14/45 12/46 | 30/26 | 1.17 (0.61; 2.24) | 0.04 (-0.14; 0.23) | 23
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, CA) for 24 weeks and then telbivudine (Idenix Pharmaceuticals, Cambridge, MA) for the remaining 28 weeks, 10 mg/day, 52 weeks
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 52 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, CA) for 24 weeks and then telbivudine (Idenix Pharmaceuticals, Cambridge, MA) for the remaining 28 weeks, 10 mg/day, 52 weeks | HBeAg seroconversion | 52/52 | 13/45 11/46 | 28/24 | 1.21 (0.61; 2.41) | 0.05 (-0.13; 0.23) | 20
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 52 weeks
Chan, 2007^44^ Telbivudine (Idenix Pharmaceuticals, Cambridge, MA), 600 mg/day in 3 tablets, 52 weeks | Primary treatment failure | 52/52 | 1/45 5/46 | 2/11 | 0.20 (0.02; 1.68) | -0.09 (-0.19; 0.01) | -12
Adjusted for baseline covariates (baseline HBV DNA level, age, body mass index, sex, and study site) odds ratio of HBV DNA PCR-negative | 52/52 | 0/45 0/45 | | 1.89 (0.72; 4.94)
Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks | Adjusted for baseline covariates odds ratio of HBeAg loss | 52/52 | 0/45 0/45 | | 1.42 (0.50; 4.07)
Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks | Adjusted for baseline covariates odds ratio of HBeAg seroconversion | 52/52 | 0/45 0/45 | | 1.49 (0.51; 4.39)
Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks
Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 52 weeks | Adjusted for baseline covariates odds ratio of primary treatment failure | 52/52 | 0/45 0/45 | | 0.05 (0.00; 0.45)
Viral breakthrough, defined as a confirmed increase in serum HBV DNA levels of greater than 1 log above the nadir value | 24/24 | 3/45 4/45 | 7/9 | 0.75 (0.18; 3.16) | -0.02 (-0.13; 0.09) | -45
Viral breakthrough was defined as an increase of serum HBV DNA to 5 log10 copies/mL or greater after a decrease to below | 24/24 | 2/45 1/45 | 4/2 | 2.00 (0.19; 21.28) | 0.02 (-0.05; 0.10) | 45

Table E5 Summary tables of the effects of drug therapies for chronic hepatitis B on outcomes

Active Treatments vs. Control Treatment | Treatment Duration/Followup Off Therapy, Weeks | Studies/Subjects Enrolled | Estimates (95 % CI) *-Dose Response Heterogeneity: p Value/I Squared, % | Level of Evidence/ Comments
(A) Virological Outcomes
HBeAg loss at the end of treatment
Adefovir dipivoxil vs. placebo^40,42^ | 48–52/0 | 2/995 | 0.11 (0.06; 0.16) (RD) 0.122/48.2 % No * | Moderate. Adefovir dipivoxil vs. placebo resulted in increased rates of HBeAg loss without dose response association
Adefovir dipivoxil+ lamivudine vs. adefovir dipivoxil^43^ | 48/0 | 1/39 | -0.01 (-0.23; 0.22) (RD) | Low. Sparse data (small N of events) No differences between adefovir dipivoxil combined with lamivudine vs. adefovir dipivoxil on HBeAg loss
Adefovir dipivoxil vs. adefovir dipivoxil then telbivudine^44^ | 52/0 | 1/91 | -0.06 (-0.23; 0.11) (RD) | Low. No differences between adefovir dipivoxil vs. adefovir dipivoxil followed by telbivudine on HBeAg loss
Adefovir dipivoxil+ lamivudine vs. lamivudine^43,58^ | 48–52/0 | 2/134 | 0.12 (0.03; 0.21) (RD) 0.699/0% | Moderate. Consistent results that adefovir dipivoxil combined with lamivudine vs. lamivudine resulted in 0.12 increase in absolute rate of HBeAg loss
Adefovir dipivoxil (10 vs.30mg)^42^ | 48/0 | 1/344 | -0.01 (-0.11; 0.08) (RD) No* | Low. Random differences between 10 and 30mg/day of adefovir dipivoxil
Adefovir dipivoxil (40 vs. 52 weeks)^40^ | 40–52/0 | 1/360 | 0.08 (-0.01; 0.16) (RD) | Low. Random differences between 40 vs. 52 weeks of adefovir dipivoxil administration
Entecavir^77^ | 24/0 | 1/76 | NS differences for all comparisons No * when 0.01; 0.1; or 0.5g were compared | Low. Sparse data (small N of events) No dose response association of entecavir on HBeAg loss.
Entecavir vs. lamivudine^73,^,^75,77^ | 24–63/0 | 3/1112 | 0.03 (-0.03; 0.08) (RD) 0.13/46.9 % | Low. No differences between entecavir vs. lamivudine on HBeAg loss
Interferon alfa 2b+corticosteroid vs. interferon alfa 2b^90,94^ | 16–24/0 | 2/77 | NS differences for all comparisons | Low. No differences between interferon Alfa 2b combined with pretreatment using corticosteroid vs. interferon Alfa 2b on HBeAg loss
Interferon alfa 2b+lamivudine vs. interferon alfa 2b^67^ | 24/0 | 1/144 | 0.00 (-0.12; 0.12) (RD) | Low. No difference between interferon Alfa 2b combined with lamivudine vs. interferon Alfa 2b on HBeAg loss
Interferon alfa 2b+lamivudine vs. interferon alfa 2b then lamivudine^80^ | 16/0 | 1/20 | 0.29 (-0.01; 0.59) (RD) | Low. No difference between interferon Alfa 2b combined with lamivudine vs. interferon Alfa 2b followed by lamivudine on HBeAg loss
Interferon alfa 2b+lamivudine vs. lamivudine^47,^,^67,69^ | 24–52/0 | 3/414 | -0.05 (-0.13; 0.03) (RD) 0.499/0% | Moderate. No difference between interferon Alfa 2b combined with lamivudine vs. lamivudine alone on HBeAg loss
Interferon alfa 2b+lamivudine vs. placebo^47^ | 52/0 | 1/118 | 0.08 (-0.05; 0.21) (RD) | Low. No effect of interferon Alfa 2b combined with lamivudine on HBeAg loss
Interferon alfa 2b vs. no treatment^89^ | 16/0 | 1/40 | 0.55 (0.29; 0.81) (RD) | Low. Interferon Alfa 2 b resulted in increased HBeAg loss compared to no treatment
Interferon alfa 2b+placebo vs. lamivudine^67^ | 24–52/0 | 1/151 | -0.03 (-0.15; 0.09) (RD) | Low. No differences between interferon Alfa 2b vs. lamivudine on HBeAg loss
Interferon alfa 2b for 48 weeks vs. interferon alfa 2b for 24 weeks^82^ | 24–48/0 | 1/65 | -0.14 (-0.36; 0.07) (RD) | Low. Treatment duration with interferon Alfa 2b did not have any effects on HBeAg loss
Lamivudine vs. adefovir dipivoxil^43^ | 48/0 | 1/38 | -0.16 (-0.34; 0.02) (RD) | Low. Sparse data (0 events in active group) No difference between lamivudine vs. adefovir dipivoxil on HBeAg loss
Lamivudine vs. placebo^47,^,^48,^,^104,112^ | 12–52/0 | 4/1349 | 0.13 (0.04; 0.22) (RD) 0.001/81% | Moderate. Non consistent effect of lamivudine on HBeAg loss
Lamivudine vs. telbivudine^72^ | 52/0 | 1/63 | -0.08 (-0.32; 0.16) (RD) | Low. No differences between lamivudine vs. telbivudine on HBeAg loss
Peginterferon alfa-2a+lamivudine vs. lamivudine^56^ | 48/0 | 1/543 | 0.05 (-0.02; 0.12) (RD) | Low. No differences between peginterferon alfa-2a combined with lamivudine vs. lamivudine on HBeAg loss
Peginterferon alfa-2a+lamivudine vs. peginterferon alfa-2a^56^ | 48/0 | 1/542 | -0.03 (-0.11; 0.05) (RD) | Low. No differences between peginterferon alfa-2a combined with lamivudine vs. peginterferon alfa-2a on HBeAg loss
Peginterferon alfa-2a+placebo vs. lamivudine^56^ | 48/0 | 1/543 | 0.08 (0.01; 0.16) (RD) | Moderate. Peginterferon alfa-2a vs. lamivudine resulted in increased absolute rate of HBeAg loss
Peginterferon alfa-2b+lamivudine vs. lamivudine^117^ | 52–60/0 | 1/100 | 0.34 (0.16; 0.52) (RD) | Moderate. Peginterferon alfa-2b combined with lamivudine vs. lamivudine resulted in increased absolute rate of HBeAg loss
Peginterferon alfa-2b+lamivudine vs. peginterferon alfa-2b^78^ | 52/0 | 1/307 | 0.12 (0.01; 0.22) (RD) | Moderate. Peginterferon alfa-2b combined with lamivudine vs. peginterferon alfa-2b resulted in increased absolute rate of HBeAg loss
Telbivudine + lamivudine vs. lamivudine^72^ | 52/0 | 1/60 | -0.09 (-0.32; 0.14) (RD) | Low. No differences between telbivudine combined with lamivudine vs. lamivudine alone on HBeAg loss
Telbivudine+lamivudine vs. telbivudine^72^ | 52/0 | 1/85 | -0.17 (-0.35; 0.01) (RD) | Low. No differences between telbivudine combined with lamivudine vs. telbivudine alone on HBeAg loss
Telbivudinevs. adefovir dipivoxil^44^ | 24–52/0 | 1/135 | NS differences for all comparisons | Low. No differences between telbivudine vs. adefovir dipivoxil alone or followed by telbivudine on HBeAg loss
HBeAg loss at the end of followup
Interferon alfa 2b+corticosteroid vs. interferon alfa 2b^90,^,^92,95^ | 16–40/24–26 | 3/122 | NS differences for all comparisons | Moderate. No differences between interferon Alfa 2b with pretreatment of corticosteroid vs. interferon Alfa 2b on HBeAg loss
Interferon alfa 2b+lamivudine vs. interferon alfa 2b^67,104^ | 24/28–40 | 2/347 | NS differences for all comparisons | Moderate. No differences between interferon Alfa 2b combined with lamivudine vs. interferon Alfa 2b on HBeAg loss
Interferon alfa 2b+lamivudine vs. lamivudine^47,^,^65,^,^67,^,^69,104^ | 37–135/16–144 | 5/1167 | 1 RCT in 5 reported significant improvement after combined therapy | Moderate. No differences between interferon Alfa 2b combined with lamivudine vs. lamivudine alone on HBeAg loss
Interferon alfa 2b+lamivudine vs. placebo^47,104^ | 24–52/16–28 | 2/450 | 0.10 (-0.04; 0.23) (RD) 0.077/68% | Moderate. No effects of interferon Alfa 2b combined with lamivudine on HBeAg loss
Interferon alfa 2b vs. lamivudine^67,104^ | 24/28–40 | 2/625 | NS differences for all comparisons | Moderate. No differences between interferon Alfa 2b and lamivudine on HBeAg loss
Interferon alfa 2b vs. interferon Alfa 2b (dose, time) ^82,90^ | 24–48/24–72 | 2/103 | NS differences for dose and duration of time comparisons | Moderate. Dose, length of treatment, or followup did not result in different effects of interferon Alfa 2b on HBeAg loss
Interferon alfa 2b vs. placebo or no treatment^86,^,^89,104^ | 16–24/8–48 | 3/351 | 0.28 (0.07; 0.50) (RD) 0.025/73 % 2.52 (1.55;4.1)(RR) 0.359/2.4 % | Moderate. All RCTs reported significant increase in HBeAg loss after interferon Alfa 2b with consistent effect size in relative risk but inconsistent increase in absolute risk
Lamivudine vs. placebo^47,48^ | 52/16 | 2/318 | 0.15 (0.05; 0.24) (RD) 0.519/0 % | Moderate. Lamivudine increased absolute rates of HBeAg loss at followup
Peginterferon alfa-2a+lamivudine vs. lamivudine^56^ | 48/24 | 1/543 | 0.07 (0.00; 0.15) (RD) | Moderate. No differences between peginterferon alfa-2a combined with lamivudine vs. lamivudine alone on HBeAg loss at followup
Peginterferon alfa-2a+lamivudine vs. peginterferon alfa-2a^56^ | 48/24 | 1/542 | -0.05 (-0.13; 0.03) (RD) | Moderate. No differences between peginterferon alfa-2a combined with lamivudine vs. peginterferon alfa-2a on HBeAg loss at time of followup
Peginterferon alfa-2a+placebo vs. lamivudine^56^ | 48/24 | 1/543 | 0.13 (0.05; 0.20) (RD) | Moderate. Peginterferon alfa-2a increased HBeAg loss compared to lamivudine at time of followup
Peginterferon alfa-2a vs. peginterferon alfa-2a^116^ | 24/24 | 1/194 | NS differences for dose and duration of time comparisons (RD) | Low. No differences between doses and length of treatment with peginterferon alfa-2a on HBeAg loss at time of followup
Peginterferon alfa-2b+lamivudine vs. peginterferon alfa-2b^78,122^ | 52/26 | 2/614 | -0.01 (-0.09; 0.06) (RD) 0.991/0% | Moderate. No difference between peginterferon alfa-2b combined with lamivudine vs. peginterferon alfa-2b alone on HBeAg loss at time of followup
Peginterferon alfa-2b+vs interferon Alfa 2b^81^ | 24/24 | 1/230 | 0.10 (0.00; 0.21) (RD) | Low. No differences between peginterferon alfa-2b vs. interferon Alfa 2b on HBeAg loss at time of followup
HBeAg seroconversion at the end of treatment
Adefovir dipivoxil +lamivudine vs. adefovir dipivoxil^43^ | 48/0 | 1/39 | -0.06 (-0.22; 0.11) (RD) | Low. Sparse data (small number of events) No differences between adefovir dipivoxil combined with lamivudine vs. adefovir dipivoxil in HBeAg seroconversion
Adefovir dipivoxil+ lamivudine vs. lamivudine^43,58^ | 48–52/0 | 2/134 | Random differences in both RCTs | Low. Sparse data (small number of events) No differences between adefovir dipivoxil combined with lamivudine vs. lamivudine on HBeAg seroconversion
Adefovir dipivoxil (dose, duration of treatment)^40,^,^42,44^ | 48–52/0 | 3/795 | Random differences in 2 RCTs from 3 (RD) No * | Low. Sparse data (small number of events) Dose and duration of treatment did not result in consistent increased rates of HBeAg seroconversion
Adefovir dipivoxil vs. placebo^40,42^ | 48–52/0 | 2/700 | 0.05 (0.01; 0.09) (RD) No * 0.25/28 % | High. Adefovir dipivoxil resulted in increased rates of HBeAg seroconversion without dose response association
Entecavir (dose response association)^77^ | 24/0 | 1/177 | NS differences for all comparisons (RD) No * association with HBeAg loss | Low. No dose response association with HBeAg loss
Entecavir vs. lamivudine^73,^,^75,77^ | 24–96/0 | 3/1185 | Random differences in 2 RCTs of 3 | Moderate. No differences between entecavir vs. lamivudine on HBeAg seroconversion
Interferon alfa 2b+lamivudine vs. interferon alfa 2b^67^ | 24/0 | 1/144 | -0.02 (-0.11; 0.07) (RD) | Low. No differences between interferon Alfa 2b combined with lamivudine vs. interferon Alfa 2b on HBeAg seroconversion
Interferon alfa 2b+lamivudine vs. lamivudine^47,^,^66,^,^67,69^ | 52/0 | 4/565 | Random differences in 3 RCTs of 4 | High. No differences between Interferon Alfa 2b combined with lamivudine vs. lamivudine alone on HBeAg seroconversion
Interferon alfa 2b+lamivudine vs. placebo^47^ | 52/0 | 1/119 | -0.01 (-0.13; 0.10) (RD) | Low. No effects from Interferon Alfa 2b+lamivudine on HBeAg seroconversion
Interferon alfa 2b+placebo vs. lamivudine^67^ | 52/0 | 1/151 | -0.05 (-0.12; 0.02) (RD) | Low. No differences between Interferon Alfa 2b and lamivudine on HBeAg seroconversion
Interferon alfa 2b ^82^ | 24/0 | 1/65 | -0.10 (-0.33; 0.12) (RD) | Low. No differences between length of treatment with interferon Alfa 2b on HBeAg seroconversion
Interferon alfa 2b vs. placebo^89^ | 16/0 | 1/40 | NS differences for dose comparisons (0.00; 0.00) (RD) | Low. No consistency across doses of interferon Alfa 2b effects on HBeAg seroconversion
Lamivudine vs. telbivudine^72^ | 52/0 | 1/63 | -0.11 (-0.34; 0.12) (RD) | Low. No differences between lamivudine vs. telbivudine on HBeAg seroconversion
Lamivudine vs. adefovir dipivoxil^43^ | 48/0 | 1/38 | -0.11 (-0.27; 0.06) (RD) | Low. No differences between lamivudine vs. adefovir dipivoxil on HBeAg seroconversion
Lamivudine ^50^ | 48/0 | 1/285 | -0.03 (-0.11; 0.05) (RD) | Low. No differences between doses of lamivudine on HBeAg seroconversion
Lamivudine vs. placebo^47,^,^48,^,^50,^,^54,^,^104,112^ | 12–80 /0 | 6/1638 | 0.05 (0.00; 0.10) (RD) 0.028/60 % 1.69 (1.05;2.74) (RR) 0.153/38 % | High. Lamivudine resulted in increased rate of HBeAg seroconversion with consistent across the RCTs results in multiplicative scale. Rate in placebo group and duration of treatments could not explain the heterogeneity in absolute rates.
Peginterferon alfa-2a+lamivudine vs. lamivudine^56^ | 48/0 | 1/543 | 0.03 (-0.04; 0.10) (RD) | Low. No differences between peginterferon alfa-2a combined with lamivudine vs. lamivudine alone on HBeAg seroconversion
Peginterferon alfa-2a+lamivudine vs. peginterferon alfa-2a^56^ | 48/0 | 1/542 | -0.03 (-0.10; 0.04) (RD) | Low. No differences between peginterferon alfa-2a+lamivudine vs. peginterferon alfa-2a
Peginterferon alfa-2a+placebo vs. lamivudine^56^ | 48/0 | 1/543 | 0.06 (-0.01; 0.13) (RD) | Low. No differences between peginterferon alfa-2a vs. lamivudine on HBeAg seroconversion
Peginterferon alfa-2b+lamivudine vs. lamivudine^117^ | 60/0 | 1/100 | 0.32 (0.14; 0.50) (RD) | Low. Peginterferon alfa-2b combined with lamivudine resulted in increase HBeAg seroconversion compared to lamivudine alone
Peginterferon alfa-2b+lamivudine vs. peginterferon alfa-2b^78^ | 52/0 | 1/307 | 0.02 (-0.07; 0.11) (RD) | Low. No differences between peginterferon alfa-2b combined with lamivudine vs. peginterferon alfa-2b alone on HBeAg seroconversion
Telbivudine+lamivudine vs. lamivudine^72^ | 52/0 | 1/60 | -0.06 (-0.28; 0.15) (RD) | Low. No differences between telbivudine combined with lamivudine vs. lamivudine on HBeAg seroconversion
Telbivudine+lamivudine vs. telbivudine^72^ | 52/0 | 1/85 | -0.17 (-0.35; 0.00) (RD) | Low. No differences between telbivudine combined with lamivudine vs. telbivudine on HBeAg seroconversion
Telbivudine vs. adefovir dipivoxil^44^ | 24–52/0 | 1/136 | 6.03 (2.20; 16.52) (RR) | Low. Telbivudine compared to adefovir dipivoxil resulted in increased relative risk of HBeAg seroconversion at 24 but not at 52 weeks of therapy without statistically significant differences in absolute rate
HBeAg seroconversion at time of followup
Interferon alfa 2b+corticosteroid vs. interferon alfa 2b^92,95^ | 24/24–26 | 2/85 | 0.10 (-0.11; 0.31) (RD) 0.792/0% | Low. No differences between Interferon Alfa 2b with Corticosteroid pretreatments vs. Interferon Alfa 2b on HBeAg seroconversion
Interferon alfa 2b+lamivudine vs. interferon alfa 2b^67,^,^79,104^ | 24–48/4–56 | 3/482 | Random difference in all comparisons. Active treatment at the longest 56 weeks of followup in 1 RCT resulted in increase of 0.36 (95 % CI 0.10; 0.61) in rate of the outcome | Low. No differences between interferon Alfa 2b combined with lamivudine vs. interferon Alfa 2b alone at followup. Limited evidence from 1 RCT suggest increase in HBeAg seroconversion at the longest 56 weeks of followup
Interferon alfa 2b+lamivudine vs. lamivudine^47,^,^66,67^ | 24–52 /16–48 | 3/490 | 0.00 (-0.15; 0.14) (RD) 0.002/84 % | Moderate. No differences between interferon Alfa 2b combined with lamivudine vs. lamivudine on HBeAg seroconversion (1 RCT from 3 reported significant increase in (0.182; 95% 0.050; 0.315)
Interferon alfa 2b+lamivudine vs. placebo^47,104^ | 24–52 /16–28 | 2/450 | 0.05 (-0.12; 0.22) (RD) 0.011/85 % | Low. No consistent effects of interferon Alfa 2b+lamivudine on HBeAg seroconversion at time of followup, secondary analysis of 4 RCTs reported significant increase (0.13; 95% 0.05: 0.21)
Interferon alfa 2b vs. lamivudine^67,104^ | 24–52 /12–40 | 3/776 | Random difference in all comparisons | Moderate. No differences between interferon Alfa 2b vs. lamivudine on HBeAg seroconversion at time of followup
Interferon alfa 2b vs. placebo^89,104^ | 16–96 /28–64 | 2/346 | 0.120 (0.03; 0.21) (RD) 0.353/0 % | Moderate Interferon Alfa 2b increased rates of HBeAg seroconversion at time of followup
Lamivudine vs. placebo^47,48^ | 52 /16 | 2/318 | Random difference in all comparisons | Low. No effects from lamivudine vs. placebo on HBeAg seroconversion at time of followup
Peginterferon alfa-2a+lamivudine vs. lamivudine^56^ | 48/24 | 1/814 | 0.08 (0.01; 0.15) (RD) | Low. Peginterferon alfa-2a combined with lamivudine vs. lamivudine results in increased rates of HBeAg seroconversion at time of followup
Peginterferon alfa-2a+lamivudine vs. peginterferon alfa-2a^56^ | 48/24 | 1/814 | -0.05 (-0.12; 0.03) (RD) | Low. No differences between peginterferon alfa-2a combined with lamivudine vs. peginterferon alfa-2a alone on HBeAg seroconversion at time of followup
Peginterferon alfa-2a+placebo vs. lamivudine^56^ | 48/24 | 1/814 | 0.13 (0.06; 0.20) (RD) | Moderate. Peginterferon alfa-2a resulted in increased rates of HBeAg seroconversion at time of followup compared to Lamivudine
Peginterferon alfa-2a vs. peginterferon alfa-2a^116^ | 24/24 | 1/194 | Random difference in all dose comparisons. No * | Low. No dose response association between peginterferon alfa-2a and HBeAg seroconversion at time of followup
Peginterferon alfa-2b+lamivudine vs. lamivudine^117^ | 52–60 /40–96 | 1/100 | Random difference in all time of followup comparisons. | Low. No differences between peginterferon alfa-2b combined with lamivudine vs. lamivudine on HBeAg seroconversion at time of followup
Peginterferon alfa-2b+lamivudine vs. peginterferon alfa-2b^78^ | 52/26 | 1/307 | Random difference in all comparisons | Low. No differences between peginterferon alfa-2b combined with lamivudine vs. peginterferon alfa-2b on HBeAg seroconversion at time of followup
HBsAg loss at the end of treatment
Adefovir dipivoxil+ lamivudine vs. adefovir dipivoxil^43^ | 48/0 | 1/39 | 0.05 (-0.08; 0.18) (RD) | Low. No differences between adefovir dipivoxil + lamivudine vs. adefovir dipivoxil on HBsAg loss
Adefovir dipivoxil+ Lamivudine vs. lamivudine^43^ | 48/0 | 1/39 | 0.05 (-0.08; 0.18) (RD) | Low. No differences between adefovir dipivoxil+ lamivudine vs. lamivudine on HBsAg loss
Adefovir dipivoxil (240 vs. 114 weeks)^97^ | 240 vs. 114 | 1/250 | -0.048 (-0.088; -0.008) (RD) | Low. Treatment with adefovir for 240 weeks resulted in decreased rates of HBsAg loss compared to 114 weeks.
Entecavir vs. lamivudine^73,101^ | 52–96 /0 | 2/1117 | Random difference in all comparisons. | Moderate. No differences between entecavir vs. lamivudine on HBsAg loss
Interferon alfa 2b+corticosteroid vs. interferon alfa 2b^94,96^ | 16–24 /0 | 2/125 | Random difference in all comparisons | Moderate. No differences between Interferon Alfa 2b with corticosteroid pretreatment vs. Interferon Alfa 2b
Interferon alfa 2b+corticosteroid vs. no treatment^96,103^ | 24/0 | 2/103 | 0.11 (0.02; 0.20) (RD) 0.917/0 % | Moderate. Interferon alfa 2b with corticosteroid pretreatment resulted in increased rates of HBsAg loss
Interferon alfa 2b+lamivudine vs. lamivudine^47,64^ | 52–96 /0 | 2/262 | Random difference in all comparisons | Moderate. No differences between interferon Alfa 2b combined with lamivudine vs. lamivudine alone on HBsAg loss
Interferon alfa 2b+lamivudine vs. placebo^47^ | 52/0 | 1/119 | 0.06 (0.00; 0.13) (RD) | Low. No differences between interferon Alfa 2b combined with lamivudine vs. placebo on HBsAg loss
Interferon alfa 2b vs. interferon alfa 2b^96^ | 24/0 | 1/82 | 0.10 (-0.01; 0.21) (RD) No * | Low. No dose response association with interferon Alfa 2b and HBsAg loss
Interferon alfa 2b vs. no treatment^84,^,^89,96^ | 16–96 /0 | 3/166 | 0.06 (-0.03; 0.15) (RD) 0.209/36.2 % | Moderate. No effects of interferon alfa 2b vs. no treatment on HBsAg loss
Lamivudine vs. placebo^47^ | 52/0 | 1/175 | 0.02 (-0.02; 0.05) (RD) | Low. Sparse data (0 events in control group) No effects of lamivudine on HBsAg loss
Peginterferon alfa-2b+lamivudine vs. peginterferon alfa-2b^78^ | 52/0 | 1/307 | 0.01 (-0.04; 0.06) (RD) | Low. No differences between peginterferon alfa-2b combined with lamivudine vs. peginterferon alfa-2b alone on HBsAg loss
HBsAg loss at followup
Interferon alfa 2b vs. no treatment^83,^,^84,^,^86,89^ | 16–96 /8–48 | 4/247 | Random difference in all comparisons. (RD) | Low. Sparse data (0 events in control group) No effects from interferon Alfa 2b vs. no treatment on HBsAg loss
Interferon alfa 2b+lamivudine vs. lamivudine^47,^,^62,66^ | 24–52 /16–48 | 3/495 | Random difference in all comparisons | Low. Sparse data (0 events in both group) No differences between interferon Alfa 2b combined with lamivudine vs. lamivudine on HBsAg loss
Interferon alfa 2b+lamivudine vs. placebo^47^ | 52/16 | 1/119 | 0.05 (-0.01; 0.11) (RD) | Low. Sparse data (0 events in control group) No effects from Interferon alfa 2b combined with lamivudine vs. placebo on HBsAg loss
Interferon alfa 2b vs. interferon Alfa 2b^82,85^ | 24–48 /48 | 2/103 | Random difference in all comparisons. No * | Low. Sparse data (0 events in both group) No dose response and time to treat association of Interferon alfa 2b on HBsAg loss
Interferon alfa 2b+corticosteroid vs. interferon alfa 2b^91,^,^92,95^ | 24/24–26 | 3/141 | Random difference in all comparisons | Low. Sparse data (small number of events) No differences between interferon alfa 2b with corticosteroid pretreatment vs. interferon Alfa 2b on HBsAg loss
Lamivudine vs. placebo^46^–^48^ | 52–96 /16–26 | 3/1068 | Random difference in all comparisons. (RD) | Low. Sparse data (small number of events) No effects from lamivudine vs. placebo on HBsAg loss at time of followup
HBsAg seroconversion - end of treatment
Adefovir dipivoxil vs. placebo^98^ | 96 weeks/0 | 1/120 | 0.01 (-0.03; 0.06) (RD) | Low. Adefovir dipivoxil did not increase rates of HBsAg seroconversion
Adefovir dipivoxil (longer treatment)^97,98^ | 48–240weeks/0 | 2/390 | Random difference in all comparisons. (RD) | Low. Adefovir dipivoxil administration for 96 vs.48 and for 240 vs. 114 weeks did not increase HBsAg seroconversion
Entecavir vs. lamivudine^101^ | 96/0 | 1/408 | -0.02 (-0.06; 0.01) | Low. Random differences between entecavir vs. lamivudine on HBsAg seroconversion
HBsAg seroconversion at followup
Peginterferon alfa-2b vs. interferon alfa 2b^81^ | 24/24 | 1/230 | Random difference in all comparisons | Low. No differences between peginterferon alfa-2b and interferon alfa 2b on HBsAg seroconversion at time of followup
Interferon alfa 2b vs. placebo^84^ | 96/48 | 1/42 | 0.10 (-0.05; 0.24) (RD) | Low. Interferon alfa 2b did not increase HBsAg seroconversion
Interferon alfa 2b vs. no treatment^89^ | 16/48–64 | 1/40 | 0.15 (-0.05; 0.35) (RD) | Low. Interferon alfa 2b did not increase HBsAg seroconversion
HBV DNA loss—end of treatment
Adefovir dipivoxil+ lamivudine vs. lamivudine^43,58^ | 48–52/0 | 2/134 | 0.25 (0.10; 0.39) (RD) 0.219/34 % | Low. Sparse data (0 events in control group) Adefovir dipivoxil+ lamivudine vs. lamivudine resulted in increased rates of HBV DNA loss
Adefovir dipivoxil vs. adefovir dipivoxil^40,^,^42,^,^44,^,^97,98^ | 48–240/0 | 5/1520 | -0.08 (-0.16; 0.01) (RD) 0.049/58 % 0.84 (0.68; 1.04) (RR) 0.034/62 % | Moderate. Duration of treatment with adefovir dipivoxil was not association with increased rates of HBV DNA loss. One RCT reported greater HBV DNA loss after 30 vs. 10 mg (0.18; 95% CI 0.08; 0.27)
Adefovir dipivoxil+ lamivudine vs. adefovir dipivoxil^43^ | 48/0 | 1/39 | 0.09 (-0.20; 0.37) (RD) | Low. No differences between adefovir dipivoxil+ lamivudine vs. adefovir dipivoxil on HBV DNA loss
Adefovir dipivoxil vs. placebo^40^–^42,98^ | 48–96 /0 | 4/1002 | 0.38 (0.23; 0.53) (RD) 0/93 % 20.41 (6.79; 61.32) (RR) 0.267/24 % | High. Adefovir dipivoxil vs. placebo resulted in increased HBV DNA loss
Entecavir (dose)^77^ | 24/0 | 1/177 | Random difference in all dose comparisons. No * | Low. No dose response association with HBV DNA loss
Entecavir vs. lamivudine^73,^,^74,^,^77,101^ | 24–96/0 | 4/1636 | 0.23 (0.11; 0.35) (RD) 0/89 % No * | Low. Entecavir vs. lamivudine resulted in greater HBV DNA loss
Entecavir vs. lamivudine^73,^,^74,^,^77,101^ | 24–96/0 | 4/1636 | 1.64 (1.22; 2.22) (RR) 0/92 % No * | Rate in control group and dose of entecavir could not explain heterogeneity across the studies.
0.30 (0.16; 0.44) (RD > 1 year of active treatment) 0.09 (-0.04; 0.21) (RD, 6 months of active treatment) | Moderate. Length of active treatment was associated with greater differences in absolute rates of HBV DNA loss with significant differences after >1 year of treatment
Interferon alfa 2b+corticosteroid vs. interferon alfa 2b^90,94^ | 16–24/0 | 2/77 | Random difference in all dose comparisons | Low. No differences between interferon alfa 2b with corticosteroid pretreatments vs. interferon alfa 2b alone on HBV DNA loss
Interferon alfa 2b+corticosteroid vs. no treatment^94^ | 16/0 | 1/34 | 0.25 (0.04; 0.46) (RD) | Low. Interferon alfa 2b with corticosteroid pretreatments vs. no treatment increased rates of HBV DNA loss
Interferon alfa 2b+lamivudine vs. interferon alfa 2b^67^ | 24/0 | 1/144 | 0.00 (-0.12; 0.12) (RD) | Low. No differences between interferon alfa 2b+lamivudine vs. interferon Alfa 2b alone on HBV DNA loss
Interferon alfa 2b+lamivudine vs. interferon alfa 2b+lamivudine^80^ | 16/0 | 1/20 | 0.00 (-0.21; 0.21) (RD) | Low. No differences between Interferon alfa 2b+lamivudine for 20 weeks vs. interferon alfa 2b +4 weeks placebo then 12 weeks lamivudine on HBV DNA loss
Interferon alfa 2b+lamivudine vs. lamivudine^47,^,^63,^,^64,66^–^69^ | 24–96/0 | 7/786 | 0.03 (-0.11; 0.17) (RD) 0/81% | High. No differences between interferon alfa 2b+lamivudine vs. lamivudine alone on HBV DNA loss
Interferon alfa 2b+lamivudine vs. placebo^47^ | 52/0 | 1/119 | 0.48 (0.33; 0.63) (RD in HBV DNA response: <3pg/ml) | Low. Inconsistent effect of interferon alfa 2b+lamivudine vs. placebo in one RCT: significant increase in rate of HBV <3pg/ml with random differences in sustained HBV DNA response
0.05 (-0.09; 0.18) (RD in sustained HBV DNA response: no two consecutive detectable HBV DNA)
Interferon alfa 2b+placebo vs. lamivudine^67^ | 24/0 | 1/76 | -0.03 (-0.15; 0.09) (RD)
Interferon alfa 2b vs. interferon alfa 2b^82,^,^85,90^ | 0/0 | 3/141 | Random difference in all dose comparisons. No * | Moderate. Different length of treatment and doses of Interferon alfa 2b were associated with random changes in HBV DNA loss
Interferon alfa 2b vs. no treatment^94^ | 16/0 | 1/34 | 0.45 (0.22; 0.68) (RD) | Low. Interferon alfa 2b vs. no treatment increased rate of HBV DNA loss
Lamivudine vs. adefovir dipivoxil^43^ | 48/0 | 1/38 | -0.26 (-0.47; -0.06) (RD) | Low. Adefovir dipivoxil vs. lamivudine increased rate of HBV DNA loss
Lamivudine^50,^,^109,110^ | 24–104/0 | 3/581 | 0.21 (0.10; 0.31) (RD) 0.187/35 % * association | Moderate. Larger doses of lamivudine resulted in greater HBV DNA loss, the length of treatment was not associated with greater dose response
Lamivudine 60 vs.48 weeks^108^ | 60/0 | 1/429 | -0.08 (-0.08; 0.2) (RD) | Low. Longer treatment did not increase HBV DNA loss
Lamivudine vs. placebo or usual care^46^–^48,^,^50,^,^53,^,^108,110^ | 12–104/0 | 7/1305 | 0.48 (0.31; 0.66) (RD) 0/94 % 3.79 (2.71; 5.30) (RR) 0.046/53 % | High. Lamivudine vs. placebo or usual care increased HBV DNA loss in all RCT with consistent effect size in relative but not absolute scale (heterogeneity significant and cannot be explained by length of treatment or control rate of HBV DNA loss)
Peginterferon alfa-2a+ lamivudine vs. lamivudine^56^ | 48/0 | 1/543 | 0.29 (0.21; 0.37) (RD) | Moderate. Peginterferon alfa-2a+ lamivudine vs. lamivudine alone increased HBV DNA loss
Peginterferon alfa-2a+ lamivudine vs. peginterferon alfa-2a^56^ | 48/0 | 1/542 | 0.44 (0.36; 0.51) (RD) | Moderate. Peginterferon alfa-2a+ lamivudine vs. peginterferon alfa-2a alone increased HBV DNA loss
Peginterferon alfa-2a+ placebo vs. lamivudine^56^ | 48/0 | 1/543 | -0.15 (-0.22; -0.07) (RD) | Moderate. Rate of HBV DNA loss was lower after peginterferon alfa-2a+ placebo vs. lamivudine
Peginterferon alfa-2b+ lamivudine vs. lamivudine^59^ | 60/0 | 1/100 | 0.06 (-0.04; 0.16) (RD) | Low. No differences between peginterferon alfa-2b+ lamivudine vs. lamivudine alone on HBV DNA loss
Lamivudine vs. telbivudine^72^ | 52/0 | 1/63 | -0.30 (-0.55; -0.04) (RD) | Low. Rate of HBV DNA loss was lower after lamivudine vs. telbivudine
Telbivudine+lamivudine vs. lamivudine^72^ | 52/0 | 1/60 | 0.17 (-0.09; 0.43) (RD) | Low. No differences between telbivudine + lamivudine vs. lamivudine alone on HBV DNA loss
Telbivudine+lamivudine vs. telbivudine^72^ | 52/0 | 1/85 | -0.13 (-0.34; 0.08) (RD) | Low. No difference between telbivudine + lamivudine vs. telbivudine alone on HBV DNA loss
Telbivudine vs. adefovir dipivoxil^44^ | 24–52/0 | 1/136 | 0.28 (0.12; 0.44) (RD) | Low. Telbivudine resulted in greater HBV DNA loss compared to adefovir dipivoxil at 24 but not 52 weeks of treatment
HBV DNA loss at time of followup
Adefovir dipivoxil vs. placebo^98^ | 96/18 | 1/120 | 0.59 (0.46; 0.72) (RD) | Low. Adefovir dipivoxil vs. placebo increased HBV DNA loss
Entecavir vs. lamivudine^73^ | 52/24 | 1/709 | 0.01 (-0.02; 0.05) (RD) | Low. No differences between entecavir vs. lamivudine on HBV DNA loss
Interferon alfa 2b+corticosteroid vs. interferon alfa 2b^90^–^92,94^–^96^ | 16–24 /24–72 | 6/322 | Random differences in all comparisons | High. No differences between interferon alfa 2b+corticosteroid vs. interferon Alfa 2b alone on HBV DNA loss
Interferon alfa 2b+corticosteroid vs. no treatment^94,96^ | 16–96 /24 | 2/121 | Random differences in all comparisons | Moderate. No effects from Interferon alfa 2b+ corticosteroid vs. no treatment on HBV DNA loss
Interferon alfa 2b+lamivudine vs. interferon alfa 2b^67,79^ | 24–48 /4–56 | 2/278 | 0.15 (-0.06; 0.35) (RD) 0.002/80.4 % | Low. No differences between interferon alfa 2b+ lamivudine vs. interferon alfa 2b alone. One RCT of treatment with lamivudine followed by combined therapy reported random differences in HBV DNA. Heterogeneity cannot be explained by the length of the treatment or followup.
Interferon alfa 2b+lamivudine vs. lamivudine^63,^,^65,^,^67,69^ | 24–176/12–40 | 4/365 | 0.04 (-0.07; 0.14) (RD) 0.071/57 % | Moderate. No differences between interferon alfa 2b + lamivudine vs. lamivudine alone on HBV DNA
Interferon alfa 2b+placebo vs. lamivudine^67^ | 24–52 /12–40 | 1/151 | Random differences in all followup comparisons | Low. No differences between interferon alfa 2b+ placebo vs. lamivudine on HBV DNA loss
Interferon alfa 2b vs. interferon alfa 2b^82,^,^85,^,^90,96^ | 24–48 /24–72 | 4/297 | Random differences in all dose, length of treatment, and followup comparisons | Moderate. No differences between doses and length of treatment of interferon alfa 2b on HBV DNA loss
Interferon alfa 2b vs. no treatment^86,94^ | 16/8–24 | 3/168 | 0.44 (0.27; 0.60) (RD) 0.573/0 % | Low. Interferon Alfa 2b vs. no treatment resulted in HBV DNA loss.
^96^ | | | 0.28 (-0.04; 0.60) (RD) 0/89 % | The effects were attenuated at longer followup
Lamivudine vs. placebo^46^ | 96/24 | 1/136 | 0.08 (0.01; 0.15) (RD) | Low. Lamivudine vs. placebo increased HBV DNA loss at time of followup
Peginterferon alfa-2a+lamivudine vs. lamivudine^56^ | 48/24 | 1/543 | 0.09 (0.04; 0.13) (RD) | Low. Peginterferon alfa-2a+lamivudine vs. lamivudine increased HBV DNA loss at time of followup
Peginterferon alfa-2a+lamivudine vs. peginterferon alfa-2a^56^ | 48/24 | 1/542 | -0.01 (-0.07; 0.05) (RD) | Low. No differences between peginterferon alfa-2a+lamivudine vs. peginterferon alfa-2a alone on HBV DNA loss at time of followup
Peginterferon alfa-2a+placebo vs. lamivudine^56^ | 48/24 | 1/543 | 0.09 (0.04; 0.14) (RD) | Low. Peginterferon alfa-2a+placebo vs. lamivudine increased rate of HBV DNA loss at followup
Peginterferon alfa-2b+lamivudine vs. lamivudine^117^ | 52–60/24–57 | 1/100 | 0.00 (-0.04; 0.04) (RD) | Low. No differences between peginterferon alfa-2b+ lamivudine vs. lamivudine on HBV DNA loss at followup
(B) Histological Outcomes
Histological improvement at end of treatment
Adefovir dipivoxil vs. placebo^41,^,^42,98^ | 48–96/0 | 3/819 | 0.26 (0.17; 0.34) (RD) 0.086/55 %. No * | High. Adefovir dipivoxil improved necroinflammatory scores compared to placebo
Adefovir dipivoxil vs. placebo^41,42^ | 48–96/0 | 2/699 | 0.20 (0.14; 0.26) (RD) 0.395/0 % No * | Moderate. Adefovir dipivoxil vs. placebo improved fibrosis scores without dose response association
Lamivudine vs. placebo^46,^,^48,^,^50,111^ | 48–96/0 | 4/580 | 0.25 (0.13; 0.38) (RD) 0.025/68 % 2.09 (1.60; 2.74) (RR) | Moderate. Lamivudine improved necroinflammatory scores in all RCT with consistent increase in relative risk and significant heterogeneity in pooled absolute risk
Adefovir dipivoxil vs. adefovir dipivoxil, 30^42,^,^97,98^ | 48–240/0 | 3/905 | Random difference in all comparisons. No * | Moderate. Dose and duration of treatments with adefovir were not associated with improved histology
Entecavir vs. lamivudine^73^–^75^ | 52–63/0 | 3/1633 | 0.14 (0.04; 0.24) (RD) 0.003/83 % No * | Moderate. Entecavir compared to lamivudine improved necroinflammatory scores without dose response association
Entecavir vs. lamivudine^73,75^ | 52–63/0 | 2/995 | 0.10 (-0.02; 0.22) (RD) 0.008/86 % No * | Moderate. No differences between entecavir vs. lamivudine on fibrosis scores
Interferon Alfa 2b +lamivudine vs. lamivudine^47,^,^68,69^ | 24–52/0 | 3/327 | -0.04 (-0.17; 0.09) (RD) 0.185/36 % | Moderate. No differences between interferon Alfa 2b combined with lamivudine vs. lamivudine on HAI scores
Interferon Alfa 2b +lamivudine vs. lamivudine^47,66^ | 52/0 | 2/389 | 0.00 (-0.38; 0.38) (RD) 0/93 % | Low. No differences between Interferon Alfa 2b combined with lamivudine vs. lamivudine on necroinflammatory scores
Lamivudine for 144 vs. 96 weeks^107^ | 96–144/0 | 1/250 | -0.16 (-0.24; -0.08) (RD) | Low. Lamivudine treatment for 144 vs. 96 weeks resulted in lower rates of Improved necroinflammatory scores.
Interferon Alfa 2b+lamivudine vs. interferon Alfa 2b^79^ | 48/0 | 1/48 | 0.54 (0.28; 0.79) (RD) | Low. Interferon Alfa 2b+lamivudine vs. interferon Alfa 2b improved HAI scores
Interferon Alfa 2b+lamivudine vs. placebo^47^ | 52/0 | 1/119 | Random difference in total and inflammatory scores | Low. Interferon Alfa 2b+lamivudine vs. placebo did not improve total and inflammatory scores
Interferon Alfa 2b vs. no treatment^84^ | 96/0 | 1/72 | 0.24 (0.00; 0.48) (RD) | Low. Interferon Alfa 2b vs. no treatment did not improve HAI scores
Peginterferon alfa-2b+lamivudine vs. lamivudine^59^ | 52–60/0 | 1/100 | Random difference in inflammatory and fibrosis scores | Low. No differences between peginterferon alfa-2b combined with lamivudine vs. lamivudine alone on inflammatory and fibrosis scores
Peginterferon alfa-2b+lamivudine vs. peginterferon alfa-2b^78^ | 52/0 | 1/307 | -0.04 (-0.12; 0.05) (RD) | Low. No differences between peginterferon alfa-2b+ lamivudine vs. peginterferon alfa-2b on inflammatory scores
Histological improvement at followup
Interferon alfa 2b+lamivudine vs. interferon alfa 2b^67^ | 24/28 | 1/144 | -0.08 (-0.23; 0.07) (RD) | Low. No differences between interferon alfa 2b+lamivudine vs. interferon alfa 2b on Knodell scores
Interferon alfa 2b+lamivudine vs. lamivudine^67^ | 24/28 | 1/157 | -0.10 (-0.24; 0.05) (RD) | Low. No differences between interferon alfa 2b+lamivudine vs. lamivudine on Knodell scores
Interferon alfa 2b+placebo vs. lamivudine^67^ | 24/28 | 1/151 | -0.02 (-0.17; 0.14) (RD) | Low. Interferon alfa 2b vs. lamivudine did not improve Knodell scores
Interferon alfa 2b vs. no treatment^89^ | 16/48 | 1/40 | 0.15 (-0.05; 0.35) (RD) | Low. Interferon alfa 2b vs. no treatment did not improve total scores
Peginterferon alfa-2a+lamivudine vs. lamivudine^56,57^ | 48/24 | 2/1366 | Random difference in all comparisons | High. No differences between peginterferon alfa-2a+lamivudine vs. lamivudine on histological improvement
Peginterferon alfa-2a+lamivudine vs. peginterferon alfa-2a^56^ | 48/24 | 1/96 | 0.04 (-0.05; 0.12) (RD) | Low. No differences between peginterferon alfa-2a + lamivudine vs. peginterferon alfa-2a on histological improvement
Peginterferon alfa-2b+lamivudine vs. peginterferon alfa-2b^78^ | 52/26 | 1/307 | 0.03 (-0.04; 0.09) (RD) | Low. No differences between peginterferon alfa-2b + lamivudine vs. peginterferon alfa-2b on fibrosis scores
Peginterferon alfa-2+placebo vs. lamivudine^57^ | 48/24 | 1/552 | -0.01 (-0.07; 0.06) (RD) | Low. No differences between peginterferon alfa-2a vs. lamivudine on fibrosis scores
Peginterferon alfa-2a+placebo vs. lamivudine^56,57^ | 48/24 | 2/1366 | Random difference in all comparisons | Moderate. No differences between peginterferon alfa-2a vs. lamivudine on HAI scores
Peginterferon alfa-2a+placebo vs. lamivudine^57^ | 48/24 | 1/552 | 0.12 (0.02; 0.22) (RD) | Low. Peginterferon alfa-2a vs. lamivudine improved necroinflammatory scores
(C) Biochemical Outcomes
ALT normalization end of treatment
Adefovir dipivoxil+ lamivudine vs. adefovir dipivoxil^43^ | 48/0 | 1/39 | 0.03 (-0.29; 0.34) (RD) | Low. No difference between Adefovir dipivoxil+ Lamivudine vs. Adefovir dipivoxil alone on ALT normalization
Adefovir dipivoxil+ lamivudine vs. lamivudine^43,58^ | 48–52/0 | 2/134 | 0.32 (0.13; 0.52) (RD) 0.158/50% | Moderate. Adefovir dipivoxil+ lamivudine vs. lamivudine increased ALT normalization
Adefovir dipivoxil (dose or duration)^40,^,^42,^,^44,^,^97,98^ | 48–240/0 | 5/173 | -0.06 (-0.12; -0.01) (RD for shorter treatment vs. longest) 0.709/0% No * | Longer treatment with adefovir associated with increased rate of ALT normalization
Adefovir dipivoxil vs. placebo^41^,^40,^,^42,98^ | 48–96/0 | 5/1342 | 0.40 (0.30; 0.49) (RD) 0.007/72% No * | High. Adefovir dipivoxil vs. placebo increased rates of ALT normalization in all RCT. The effect size was consistent in multiplicative scale. Heterogeneity in ARD could not be explained by the dose, control rate, duration of the treatment, % of HBeAg + patients
2.97 (2.38; 3.69) (RR) 0.219/30 %
Entecavir (dose)^76,77^ | 24–48/0 | 2/359 | Random differences in all dose comparisons No * | Moderate. No dose response association of entecavir on ALT normalization
Entecavir vs. lamivudine^73^–^77,101^ | 24–96/0 | 6/2423 | 0.22 (0.11; 0.32) (RD) 0/87% | High. Entecavir vs. lamivudine increased rate of ALT normalization. Heterogeneity was significant in relative and absolute risk differences. Heterogeneity did not depend on dose of entecavir, duration of treatment, or % of HBeAg + patients.
1.62 (1.28; 2.06) (RR) 0/87% | The effect of entecavir on ARD of ALT normalization was lower in RCTs with higher rates of the outcome after lamivudine administration (meta-regression -0.004, p=0.005)
Interferon alfa 2b+lamivudine vs. interferon alfa 2b^67^ | 24/0 | 1/144 | -0.01 (-0.14; 0.11) (RD) | Low. No differences between interferon alfa 2b+lamivudine vs. interferon alfa 2b on ALT normalization
Interferon alfa 2b+lamivudine vs. interferon alfa 2b+lamivudine^80^ | 16/0 | 1/20 | -0.05 (-0.42; 0.32) (RD) | Low. No differences between interferon alfa 2b+lamivudine vs. interferon alfa 2b followed by lamivudine on ALT normalization
Interferon alfa 2b+lamivudine vs. lamivudine^47,^,^62,^,^63,^,^67,69^ | 24–96/0 | 5/626 | -0.02 (-0.16; 0.12) (RD) 0.004/74% | Moderate. No differences between interferon alfa 2b+lamivudine vs. lamivudine alone on ALT normalization
Interferon alfa 2b+lamivudine vs. placebo^47^ | 52/0 | 1/119 | 0.03 (-0.10; 0.16) (RD) | Low. Interferon alfa 2b+lamivudine vs. placebo did not increase rates of ALT normalization
Interferon alfa 2b+placebo vs. lamivudine^67^ | 24/0 | 1/151 | -0.04 (-0.15; 0.07) (RD) | Low. No differences between Interferon alfa 2b+placebo vs. lamivudine on ALT normalization
Interferon alfa 2b ^82,85^ | 24–48/0 | 2/103 | Random differences in all dose and time comparisons | Low. Dose and duration of interferon alfa 2b therapy was not associated with increased rates of ALT normalization
Lamivudine vs. adefovir dipivoxil^43^ | 48/0 | 1/38 | -0.42 (-0.67; -0.18) (RD) | Low. Adefovir dipivoxil increased rates of ALT normalization compared to lamivudine
Lamivudine ^50^,^55,108^ | 48–52/0 | 3/838 | Random differences in all dose and time comparisons | Moderate. Dose and duration of lamivudine therapy was not associated with increased rates of ALT normalization
Lamivudine vs. no treatment or placebo^54^,^46^–^48,^,^50,^,^108,112^ | 12–96 /0 | 7/1602 | 0.22 (0.13; 0.31) (RD) 0/78% | Moderate. Lamivudine increased ALT normalization with consistent effect size in relative risk. An increase in absolute risk was inconsistent across the studies; heterogeneity cannot be explained by the length of the treatment, control rate, or % of HBeAg + patients.
2.42 (1.94; 3.01) (RR) 0.44/0%
Lamivudine vs. telbivudine^72^ | 52/0 | 1/85 | Random differences in two of three dose comparisons | Low. No differences between lamivudine vs. different doses of telbivudine on ALT normalization
Peginterferon alfa-2a+lamivudine vs. lamivudine^56,57^ | 48/0 | 2/905 | -0.20 (-0.29; -0.10) (RD) 0.141/54% | High. Peginterferon alfa-2a+lamivudine vs. lamivudine resulted in lower rates of ALT normalization
Peginterferon alfa-2a+lamivudine vs. peginterferon alfa-2a^56^ | 48/0 | 1/542 | 0.08 (-0.01; 0.16) (RD) | Low. No differences between peginterferon alfa-2a+lamivudine vs. peginterferon alfa-2a alone on ALT normalization
Peginterferon alfa-2a+placebo vs. lamivudine^57^,^56^ | 48/0 | 2/905 | -0.29 (-0.42; -0.17) (RD) 0.045/75% | Moderate. Peginterferon alfa-2a+placebo vs. lamivudine alone reduced rates of ALT normalization with consistent effect size in relative risk and significant heterogeneity in pooled ARD
0.57 (0.46; 0.70) (RR) 0.13/56%
Peginterferon alfa-2b+lamivudine vs. lamivudine^59^ | 60/0 | 1/100 | 0.12 (-0.02; 0.26) (RD) | Low. No differences between peginterferon alfa-2b+lamivudine vs. lamivudine alone on ALT normalization
Peginterferon alfa-2b+lamivudine vs. peginterferon alfa-2b^78^ | 52/0 | 1/307 | 0.14 (0.03; 0.24) (RD) | Low. Peginterferon alfa-2b+lamivudine vs. peginterferon alfa-2b alone increased rate of ALT normalization
Telbivudine+lamivudine vs. lamivudine^72^ | 52/0 | 1/101 | Random differences in all 3 dose comparisons | Low. Three tested doses of telbivudine + lamivudine vs. lamivudine alone did not increase rates of ALT normalization
Telbivudine+lamivudine vs. telbivudine^72^ | 52/0 | 1/101 | Random differences in all 3 dose comparisons | Low. Three tested doses of Telbivudine + lamivudine vs. telbivudine alone did not increase rates of ALT normalization
Telbivudine vs. telbivudine^72^ | 52/0 | 1/44 | 0.09 (-0.11; 0.29) (RD) No * association | Low. Telbivudine 600mg vs. telbivudine 400mg did not improve rates of ALT normalization
Telbivudine vs. adefovir dipivoxil^44^ | 24–52/0 | 1/135 | Random differences in all dose and time comparisons | Low. No differences between telbivudine vs. adefovir dipivoxil on ALT normalization
ALT normalization at followup
Adefovir dipivoxil vs. placebo^40,98^ | 12–96/18–40 | 2/600 | 0.26 (0.19; 0.33) (RD) 0.791/0% | Moderate. Adefovir dipivoxil vs. placebo increased rates of ALT normalization at followup
Interferon alfa 2b+corticosteroid vs. interferon alfa 2b^92,^,^95,96^ | 24/24–26 | 3/170 | Random differences in all comparisons | Moderate. No differences between interferon Alfa 2b+corticosteroid vs. interferon alfa 2b alone on ALT normalization at time of followup
Interferon alfa 2b+corticosteroid vs. no treatment^96^ | 24/24 | 1/87 | 0.25 (0.06; 0.43) (RD) | Low. Interferon Alfa 2b+corticosteroid vs. no treatment increased rate of ALT normalization
Interferon alfa 2b+lamivudine vs. interferon alfa 2b^67,79^ | 24–48 /4–56 | 2/192 | Random differences in all time of followup comparisons, significant increase in RD at the onset 56 week time of followup | Low. No differences between interferon alfa 2b+lamivudine vs. interferon Alfa 2b on ALT normalization at 4–40 weeks of followup, a significant increase in the outcome at 56 weeks
Interferon alfa 2b+lamivudine vs. lamivudine^63^ | 24–176 /24–96 | 6/751 | 0.03 (-0.03; 0.08) (RD) 0.014/58.3% | Moderate. No differences between interferon alfa 2b+lamivudine vs. lamivudine on ALT normalization at time of followup
^62,65^–^67,69^ | 2 of 6 RCT reported an increase in rate, heterogeneity cannot be explained by length of the treatment and followup, or dose of interferon alfa 2b
Interferon alfa 2b+placebo vs. lamivudine^67^ | 24/12–40 | 2/151 | Random differences at different time of followup | Low. No differences between interferon alfa 2b+placebo vs. lamivudine on ALT normalization at time of followup
Interferon alfa 2b vs. interferon alfa 2b^82,^,^85,96^ | 24–48 /24–48 | 3/185 | Random differences at different doses and time of followup | Moderate. No difference between different doses or time of treatment and followup of interferon alfa 2b on ALT normalization
Interferon alfa 2b vs. no treatment^86,96^ | 16–24 /8–24 | 2/131 | 0.31 (0.17; 0.44) (RD) 0.442/0% | Moderate. Interferon Alfa 2b at doses 35 but not 7MU/week vs. no treatment increased rates of ALT normalization at time of followup
Lamivudine vs. placebo^46^ | 96/24 | 1/136 | 0.21 (0.04; 0.38) (RD) | Low. Lamivudine vs. placebo increased rates of ALT normalization at time of followup
Peginterferon alfa 2a+lamivudine vs. lamivudine^56,57^ | 48/24 | 2/905 | 0.13 (0.06; 0.19) (RD) 0.569/0% | High. Peginterferon alfa 2a+lamivudine vs. lamivudine increased rate of ALT normalization at time of followup
Peginterferon alfa 2a+lamivudine vs. peginterferon alfa-2a^56^ | 48/24 | 1/542 | -0.02 (-0.10; 0.06) (RD) | Low. No differences between peginterferon alfa-2a+lamivudine vs. peginterferon alfa 2a on ALT normalization at time of followup
Peginterferon alfa 2a+placebo vs. lamivudine^56,57^ | 48/24 | 2/905 | 0.13 (0.07; 0.20) (RD) 0.904/0% | High. Peginterferon alfa-2a+placebo vs. lamivudine alone increased rates of ALT normalization at time of followup
Peginterferon alfa 2a vs. peginterferon alfa-2a^116^ | 24/24 | 1/194 | Random differences at all dose comparisons No * | Low. No dose response association of peginterferon alfa-2a on ALT normalization at time of followup
Peginterferon alfa 2b+lamivudine vs. peginterferon alfa 2b^78^ | 52/26 | 1/307 | 0.02 (-0.08; 0.12) (RD) | Low. No differences between peginterferon alfa-2b+lamivudine vs. peginterferon alfa-2b alone on ALT normalization at time of followup
Peginterferon alfa-2b vs. interferon alfa 2b^81^ | 24/24 | 1/230 | -0.01 (-0.13; 0.11) (RD) | Low. No differences between peginterferon alfa-2b vs. interferon alfa 2b on ALT normalization at time of followup
(D) Relapse and Mutation
Relapse end of treatment
Adefovir dipivoxil vs. placebo^40,100^ | 48–52/0 | 2/1055 | -0.08 (-0.37; 0.21) (RD) 0.000/99% | Low. Adefovir dipivoxil in dose of 10mg/day increased rates of relapse. Adefovir dipivoxil in adjusted dose (10 or 30 mg/day) reduced the rate of relapse.
Entecavir vs. lamivudine^74,101^ | 52–96/0 | 2/1347 | -0.01 (-0.11; 0.09) (RD) 0/96% | Low. Entecavir vs. lamivudine reduced relapse in HBeAg negative patients but increase in HBeAg positive.
Interferon Alfa 2b+lamivudine vs. lamivudine^60,^,^63,^,^64,66^ | 24–96 /0 | 4/326 | -0.06 (-0.16; 0.04) (RD) 0.063/59% | High. No differences between interferon Alfa 2b+lamivudine vs. lamivudine alone on relapse
Lamivudine^108^ | 48–60/0 | 1/348 | 0.16 (0.08; 0.24) (RD) | Low. Lamivudine for 60 weeks vs. lamivudine for 48 weeks increased rates of virological relapse
Lamivudine vs. telbivudine^72^ | 52/0 | 1/63 | 0.11 (-0.06; 0.29) (RD) | Low. No differences between lamivudine vs. telbivudine on virological relapse
Peginterferon alfa-2b+lamivudine vs. lamivudine^59^ | 60/0 | 1/100 | Random differences for virological and biochemical outcomes | Low. No differences between peginterferon alfa-2b+lamivudine vs. lamivudine alone on relapse
Telbivudine+lamivudine vs. lamivudine^72^ | 52/0 | 1/60 | -0.04 (-0.23; 0.16) (RD) | Low. No differences between telbivudine + lamivudine vs. lamivudine on relapse
Telbivudine+lamivudine vs. telbivudine ^72^ | 52/0 | 1/85 | 0.08 (-0.04; 0.19) (RD) | Low. No differences between telbivudine+ lamivudine vs. telbivudine on relapse
Relapse at followup
Entecavir vs. lamivudine^73^ | 52/24 | 1/709 | -0.16 (-0.20; -0.12) (RD) | Low. Entecavir vs. lamivudine reduced virological relapse
Interferon Alfa 2b+corticosteroid vs. interferon Alfa 2b^91,96^ | 24/24 | 2/141 | Random differences for all comparisons | Low. No differences between interferon Alfa 2b+corticosteroid vs. interferon Alfa 2b alone on relapse
Interferon Alfa 2b+corticosteroid vs. no treatment^96^ | 24/24 | 1/87 | 0.02 (-0.04; 0.08) (RD) | Low. Interferon Alfa 2b+ corticosteroid vs. no treatment did not increase rates of relapse
Interferon Alfa 2b+lamivudine vs. lamivudine^65,69^ | 52–176/24–192 | 2/158 | Random differences in all but at 96 and 144 weeks of followup comparisons | Low. No differences between Interferon Alfa 2b + lamivudine vs. lamivudine alone on relapse at weeks 24, 48, and 192 of followup. One RCT reported a significant decrease in relapse at weeks 96 and 144 of followup
Interferon alfa 2b vs. interferon Alfa 2b^96^ | 24/24 | 1/82 | -0.02 (-0.09; 0.04) | Low. No differences between 5 or 1 MU/day of interferon Alfa 2b on relapse at followup
Interferon alfa 2b vs. no treatment^83,^,^84,^,^88,96^ | 16–96/20–96 | 5/378 | Random differences for all comparisons | High. Interferon Alfa 2b vs. no treatment did not increase rates of relapse
Peginterferon alfa 2b+lamivudine vs. lamivudine^117^ | 52–60/24–72 | 1/100 | Random differences for all time of followup comparisons (0.00; 0.00) (RD) | Low. No differences between peginterferon alfa-2b+lamivudine vs. lamivudine on relapse in all time of followup
Mutation end of treatment
Adefovir dipivoxil+lamivudine vs. lamivudine^58^ | 52/0 | 1/95 | -0.33 (-0.50; -0.17) (RD) 0.04 (-0.03; 0.11) (RD) | Low. Adefovir dipivoxil+ lamivudine vs. lamivudine decreased rates of YMDD but not wild type mutation
Adefovir dipivoxil vs. adefovir dipivoxil^97^ | 114–240/0 | 1/250 | 0.18 (0.08; 0.27) (RD) 0.12 (0.04; 0.20) (RD) | Low. Adefovir dipivoxil for 240 vs. 114 weeks increased rates of adefovir resistant mutation
Adefovir dipivoxil vs. placebo^41,100^ | 48/0 | 2/879 | Random differences for all but 1 amino acid substitution rt221Y | Low. Adefovir dipivoxil vs. placebo increased rates of emerging amino acid substitutions in the HBV-RT domain and rates of rt221Y amino acid substitution but not rt134D; rt219A; rt91I;rt134N; rt54H; rt145M substitutions
Interferon alfa 2b+lamivudine vs. lamivudine^66^ ^47,^,^60,^,^62,^,^63,69^ | 24–96 /0 | 6/721 | -0.18 (-0.35; -0.01) (RD) 0/91% | Moderate. Interferon alfa 2b+lamivudine vs. lamivudine reduced rate of mutation with inconsistent effect size. Heterogeneity cannot be explained by the dose of Interferon alfa 2b, length of treatment, or % of HBeAg + patients at baseline
0.42 (0.16; 1.09) (RR) 0.003/72.2%
Interferon Alfa 2b+lamivudine vs. placebo^47^ | 52/0 | 1/118 | 0.00 (-0.03; 0.03) (RD) | Low. No differences between interferon Alfa 2b+lamivudine vs. placebo on mutation
Lamivudine for 60 weeks vs. lamivudine for 48 weeks^108^ | 48–60/0 | 1/429 | 0.06 (0.01; 0.11) (RD) 0.03 (0.00; 0.06) (RD) | Low. Lamivudine for 60 weeks vs. lamivudine for 48 weeks increased rates of mixed and pure YMDD mutation
Lamivudine vs. placebo^47,51^ | 52–130/0 | 2/826 | 0.43 (0.38; 0.48) (RD) 0.873/0% | High. Lamivudine vs. placebo increased rates of YMDD mutation
Peginterferon alfa 2a+lamivudine vs. lamivudine^56^ | 48/0 | 1/543 | -0.22 (-0.28; -0.16) (RD) | Low. Peginterferon alfa-2a+lamivudine vs. lamivudine reduced rate of mutation
Peginterferon alfa 2a+lamivudine vs. peginterferon alfa 2a^56^ | 48/0 | 1/542 | 0.03 (0.01; 0.06) (RD) | Low. Peginterferon alfa-2a+lamivudine vs. peginterferon alfa-2a alone increased rate of mutation
Peginterferon alfa 2a+placebo vs. lamivudine^56^ | 48/0 | 1/543 | -0.25 (-0.31; -0.20) (RD) | Low. Peginterferon alfa 2a+ placebo vs. lamivudine alone reduced rate of mutation
Peginterferon alfa 2b+lamivudine vs. lamivudine^59^ | 60/0 | 1/100 | -0.18 (-0.35; -0.01) (RD) | Low. Peginterferon alfa 2b+lamivudine vs. lamivudine alone reduced rate of mutation
Peginterferon alfa 2b+lamivudine vs. peginterferon alfa 2b^78^ | 52/0 | 1/307 | 0.09 (0.04; 0.14) (RD) | Low. Peginterferon alfa 2b+lamivudine vs. peginterferon alfa-2b increased rates of mutation
Followup
Adefovir dipivoxil for 96 vs. 48 weeks^98^ | 96/18 | 1/140 | Random differences in all mutations and duration of treatment | Low. No differences in mutations after adefovir dipivoxil for 96 vs. 48 weeks
Adefovir dipivoxil vs. placebo^98^ | 96/18 | 1/140 | Random differences in all mutations and duration of treatment | Low. Adefovir dipivoxil vs. placebo did not increase rates of mutation
Interferon alfa 2b+lamivudine vs. interferon alfa 2b^67^ | 24/28 | 1/144 | 0.00 (-0.03; 0.03) (RD) | Low. No difference between Interferon alfa 2b+lamivudine vs. interferon alfa 2b on mutations at followup
Interferon alfa 2b+lamivudine vs. lamivudine^67^ | 24/28 | 1/157 | -0.23 (-0.32; -0.14) (RD) | Low. Interferon alfa 2b+lamivudine vs. lamivudine reduced mutation at followup
Interferon alfa 2b+placebo vs. lamivudine^67^ | 24/28 | 1/151 | -0.23 (-0.33; -0.14) (RD) | Low. Interferon alfa 2b+ placebo vs. lamivudine reduced mutations at followup

Bold- significant differences at 95% confidence level

Table E6 Levels of viral load, biochemical, or histologic outcomes after antiviral drugs in adults with chronic hepatitis B

Author Active Drug, Daily/Weekly Dose Combined Active Drug, Daily/Weekly Dose, Length of Active Treatment in Weeks | Control Intervention, Daily/Weekly Dose Length of Control Intervention | Patients in Active/Control Group | Time to Measure Outcomes from Randomization (Weeks) After Active/Control Treatments | Outcome | Mean± Standard Deviation After Active Treatment | Mean± Standard Deviation After Control Treatment | Mean Difference (95% CI)
Barbaro, 2001^66^ Recombinant interferon alpha-2b (Intron A, Schering Plough, Kenilworth, NJ), 4 9 million units 3 times per week Lamivudine (Glaxo-Wellcome Inc, Research Triangle Park, NC), 100mg/day, 24 weeks | lamivudine (Glaxo-Wellcome Inc, Research Triangle Park, NC), 100 mg/day, 52 weeks | 76/75 | 24/52 | Median reduction in the histological inflammation score | 4±2 | 3±1 | 0.63 (0.30; 0.96)
Yalcin, 2003^79^ IFN-a-2b, 4 10 MU 3 times per week Lamivudine, 100mg daily, 48 weeks | IFN-a-2b, 4 10 MU 3 times per week, 48 weeks | 33/16 | 48/48 | Mean of HAI score | 4±3 | 8±3 | -1.35 (-2.00; -0.69)
Robson, 1992^103^ Interferon alpha-2b (Intron A; Scherag), 4 10MI 3 times/week after 6 weeks of prednisone and 2 weeks without treatment prednisone, 4060mg/day for 2 weeks then 40mg/day for 2 weeks, and then 20mg/day for 2 weeks, 24 weeks | Symptomatic treatment, 24 weeks | 10/10 | 24/24 | WCCX10 in 9 degree | 5±2 | 7±2 | -1.20 (-2.16; -0.24)
| Symptomatic treatment, 24 weeks
| Symptomatic treatment, 24 weeks | 10/10 | 24/24 | Platelets | 111±74 | 149±69 | -0.53 (-1.42; 0.36)
| Symptomatic treatment, 24 weeks
10/10 | 24/24 | AST U/L | 96±82 | 156±106 | -0.63 (-1.53; 0.27)
10/10 | 24/24 | ALT U/L | 112±107 | 159±87 | -0.48 (-1.37; 0.41)
10/10 | 24/24 | Albumin g/L | 40±5 | 35±12 | 0.50 (-0.39; 1.39)
Akarca, 2004^64^ Interferon Alfa, 4 10 MU 3 times per week for 24 weeks Lamivudine, 150mg daily, 96 weeks | Lamivudine, 150 mg/day, 96 weeks | 40/40 | 24/24 | ALT levels | 58±37 | 36±21 | 0.73 (0.28; 1.18)
Akarca, 2004^64^ Interferon Alfa, 4 10 MU 3 times per week for 24 weeks Lamivudine, 150mg daily, 96 weeks | Lamivudine, 150 mg/day, 96 weeks
Akarca, 2004^64^ Interferon Alfa, 4 10 MU 3 times per week for 24 weeks Lamivudine, 150mg daily, 96 weeks | Lamivudine, 150 mg/day, 96 weeks | 40/40 | 96/96 | ALT levels | 28±15 | 29±26 | -0.05 (-0.49; 0.39)
40/40 | 96/96 | Necroinflammatory activity scores | 4±3 | 3±2 | 0.70 (0.25; 1.15)
40/40 | 96/96 | Fibrosis scores | 1±1 | 1±1 | 0.52 (0.07; 0.96)
Sarin, 2005^69^ IFN-α, 5 MU daily 16 weeks added after the first 8 weeks Lamivudine, 100mg/day, 52 weeks | Lamivudine, 100 mg/day, 52 weeks | 38/37 | 52/52 | ALT Levels (IU/L) | 39±11 | 44±16 | -0.35 (-0.81; 0.10)
Sarin, 2005^69^ IFN-α, 5 MU daily 16 weeks added after the first 8 weeks Lamivudine, 100mg/day, 52 weeks | Lamivudine, 100 mg/day, 52 weeks
Sarin, 2005^69^ IFN-α, 5 MU daily 16 weeks added after the first 8 weeks Lamivudine, 100mg/day, 52 weeks | Lamivudine, 100 mg/day, 52 weeks | 38/37 | 76/76 | ALT Levels (IU/L) | 77±156 | 58±24 | 0.17 (-0.28; 0.62)
38/37 | 52/52 | HBV DNA (copies/mL) | 51±29 | 120±380 | -0.26 (-0.71; 0.20)
38/37 | 76/76 | HBV DNA (copies/mL) | 227±517 | 105±405 | 0.26 (-0.19; 0.72)
Akyuz, 2007^60^ Interferon Alfa 2b, 4 10MU 3 times per week for 24 weeks Lamivudine, 100mg/day for 96 weeks | lamivudine, 100 mg/day for 96 weeks, | 21/24 | 96/96 | HAI scores | 6±16 | 3±11 | 0.18 (-0.41; 0.77)
Zarski, 1994^91^ interferon alpha-2b (INTRON A, Schering-Plough Corporation), 2 5 MU three times a week Prednisone, 40decreasing doses of 60, 40, 20 mg for 6 weeks, 24 weeks | interferon alpha-2b (INTRON A, Schering-Plough Corporation), 2 5 MU 3 times per week, 24 weeks | 31/25 | 48/48 | Knodell score | 7±4 | 6±2 | 0.16 (-0.37; 0.69)
Reichen, 1994^90^ Recombinant interferon alpha 2b (Intron), 1 1.5 MU 3 times per week Prednisone, 3750mg for 2 weeks, 25 mg for 2 weeks, then 2 weeks drug free interval, 24 weeks | Recombinant interferon alpha 2b (Intron), 1 placebo withdrawal followed 1.5 MU 3 times per week, 24 weeks | 18/19 | 48/48 | ALT level | 116±95 | 211±280 | -0.45 (-1.10; 0.20)
Recombinant interferon alpha 2b (Intron), 2 placebo withdrawal followed 5 MU 3 times per week, 24 weeks | 18/19 | 48/48 | ALT level | 116±95 | 155±242 | -0.21 (-0.86; 0.44)
Reichen, 1994^90^ Recombinant interferon alpha 2b (Intron), 1 placebo withdrawal followed 1.5 MU three times per week, 24 weeks | Recombinant interferon alpha 2b (Intron), 2 placebo withdrawal followed 5 MU 3 times per week, 24 weeks | 19/19 | 48/48 | ALT level | 211±280 | 155±242 | 0.21 (-0.42; 0.85)
Reichen, 1994^90^ Recombinant interferon alpha 2b (Intron), 1 1.5 MU 3 times per week prednisone, 3750mg for 2 weeks, 25 mg for two weeks, then 2 weeks drug free interval, 24 weeks | Recombinant interferon alpha 2b (Intron), 1 placebo withdrawal followed 1.5 MU 3 times per week, 24 weeks | 18/19 | 48/48 | Inflammation scores | 7±4 | 9±5 | -0.47 (-1.13; 0.18)
Recombinant interferon alpha 2b (Intron), 2 placebo withdrawal followed 5 MU 3 times per week, 24 weeks | 18/19 | 48/48 | Inflammation scores | 7±4 | 8±5 | -0.24 (-0.88; 0.41)
Reichen, 1994^90^ Recombinant interferon alpha 2b (Intron), 1 placebo withdrawal followed 1.5 MU three times per week, 24 weeks | Recombinant interferon alpha 2b (Intron), 2 placebo withdrawal followed 5 MU 3 times per week, 24 weeks | 19/19 | 48/48 | Inflammation scores | 9±5 | 8±5 | 0.21 (-0.43; 0.85)
Reichen, 1994^90^ Recombinant interferon alpha 2b (Intron), 1 1.5 MU 3 times per week Prednisone, 3750mg for 2 weeks, 25 mg for 2 weeks, then 2 weeks drug free interval, 24 weeks | Recombinant interferon alpha 2b (Intron), 1 placebo withdrawal followed 1.5 MU 3 times per week, 24 weeks | 18/19 | 48/48 | Fibrosis scores | 4±1 | 4±1 | 0.17 (-0.48; 0.81)
Recombinant interferon alpha 2b (Intron), 2 placebo withdrawal followed 5 MU 3 times per week, 24 weeks | 18/19 | 48/48 | Fibrosis scores | 4±1 | 3±2 | 0.56 (-0.10; 1.21)
Reichen, 1994^90^ Recombinant interferon alpha 2b (Intron), 1 placebo withdrawal followed 1.5 MU 3 times per week, 24 weeks | Recombinant interferon alpha 2b (Intron), 2 placebo withdrawal followed 5 MU 3 times per week, 24 weeks | 19/19 | 48/48 | Fibrosis scores | 4±1 | 3±2 | 0.40 (-0.25; 1.04)
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks | Baseline, 48 weeks | 271/271 | 48/48 | Reduction in HBV DNA log copies/ml | | | -7.20 (-6.90; -7.50)
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26 180 mg once weekly, 48 weeks | 48 weeks | 181/181 | 48/48 | Change in HBV DNA from baseline after Interferon+ LAM in log copies/ml | | | -5.00 (-5.30; -4.70)
Marcellin, 2004^57^ Peginterferon alfa-2a (Pegasys, Roche), 26 180 mg once weekly, 48 weeks | 48 weeks
181/181 | 48/48 | Change in HBV DNA from baseline after Interferon in log copies/ml | | | -4.10 (-4.50; -3.80)
181/181 | 72/72 | Change in HBV DNA in log copies/ml from baseline after Interferon | | | -2.30 (-1.90; -2.70)
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26 180 mg weekly Placebo, 48 weeks | Baseline, 48 weeks | 271/272 | 48/48 | Reduction in HBV DNA log copies/ml | | | -4.50 (-4.10; -4.90)
Lau, 2005^56^ Peginterferon alfa-2a (Pegasys, Roche, 26 180 mg weekly Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100mg/day, 48 weeks | Baseline, 48 weeks | 271/271 | 72/72 | Reduction in HBV DNA log copies/ml | | | -2.70 (-2.20; -3.10)
Lau, 2005^56^ peginterferon alfa-2a (Pegasys, Roche, 26 180 mg weekly Placebo, 48 weeks | Baseline, 48 weeks | 271/272 | 72/72 | Reduction in HBV DNA log copies/ml | | | -2.40 (-2.00; -2.80)
Van Zonneveld, 2006^125^ Peg-interferon α-2b, 14 100 microg/week until week 32, then 50mg/week Lamivudine, 100mg/daily, 52 weeks | Peg-interferon α-2b+Placebo, 14/ 100 microg/week, 52 weeks | 152/155 | 52/52 | Change in fibrosis score | 0±1 | 0±2 | -0.14 (-0.36; 0.09)
Van Zonneveld, 2006^125^ Peg-interferon α-2b, 14 100 microg/week until week 32, then 50mg/week Lamivudine, 100mg/daily, 52 weeks | Peg-interferon α-2b+Placebo, 14/ 100 microg/week, 52 weeks
Van Zonneveld, 2006^125^ Peg-interferon α-2b, 14 100 microg/week until week 32, then 50mg/week Lamivudine, 100mg/daily, 52 weeks | Peg-interferon α-2b+Placebo, 14/ 100 microg/week, 52 weeks | 152/155 | 52/52 | Necroinflammatory score | 4±2 | 4±2 | -0.21 (-0.43; 0.01)
Van Zonneveld, 2006^125^ Peg-interferon α-2b, 14 100 microg/week until week 32, then 50mg/week Lamivudine, 100mg/daily, 52 weeks | Peg-interferon α-2b+Placebo, 14/ 100 microg/week, 52 weeks
152/155 | 52/52 | Fibrosis score | 3±2 | 3±2 | 0.06 (-0.17; 0.28)
152/155 | 52/52 | Change in Necroinflammatory score | -2±3 | -2±2 | -0.08 (-0.31; 0.14)
152/155 | 52/52 | HBV DNA decline in log | 5±2 | 2±2 | 1.36 (1.11; 1.61)
Hadziyannis, 2005^98^ Placebo, 0 placebo after 48 weeks of adefovir therapy, 96 weeks | Adefovir dipivoxil, 10 mg daily after 48 weeks of placebo therapy, 96 weeks | 40/60 | 96/96 | Change in serum ALT, IU/liter | -63±131 | -130±213 | 0.36 (-0.04; 0.77)
Hadziyannis, 2005^98^ Placebo, 0 placebo after 48 weeks of adefovir therapy, 96 weeks | Adefovir dipivoxil, 10 mg daily after 48 weeks of placebo therapy, 96 weeks
Hadziyannis, 2005^98^ Placebo, 0 placebo after 48 weeks of adefovir therapy, 96 weeks | Adefovir dipivoxil, 10 mg daily after 48 weeks of placebo therapy, 96 weeks | 40/60 | 96/96 | Change in Knodell inflammatory scores | -1±2 | -2±4 | 0.43 (0.02; 0.83)
Hadziyannis, 2005^98^ Placebo, 0 placebo after 48 weeks of adefovir therapy, 96 weeks | Adefovir dipivoxil, 10 mg daily after 48 weeks of placebo therapy, 96 weeks
40/60 | 96/96 | Change in total Knodell scores | -1±2 | -2±5 | 0.26 (-0.15; 0.66)
40/60 | 96/96 | Change in Knodell fibrosis scores | 0±1 | 0±1 | -0.31 (-0.71; 0.10)
40/60 | 96/96 | Change in serum HBV DNA level in log copies/ml | -1±1 | -4±1 | 2.10 (1.60; 2.59)
Leung, 2001 ^106^ Lamivudine, 100 mg/day, 156 weeks | Baseline, 0 weeks | 58/58 | 156/0 | Median ALT (range) × ULN | 1±2 | 2±3 | -0.36 (-0.72; 0.01)
58/58 | 156/0 | Median HBV DNA (range) in pg/mL | 1±58 | 59±149 | -0.52 (-0.89; -0.15)
Kweon, 2001^113^ lamivudine, 100 mg/day, 52 weeks | Placebo, 52 weeks | 47/33 | 52/52 | ALT (IU/l) | 61±55 | 104±109 | -0.53 (-0.98; -0.07)
Kweon, 2001^113^ lamivudine, 100 mg/day, 52 weeks | Placebo, 52 weeks
Kweon, 2001^113^ lamivudine, 100 mg/day, 52 weeks | Placebo, 52 weeks | 47/33 | 52/52 | HAI score: Portal inflammation | 2±1 | 3±1 | -0.65 (-1.11; -0.19)
Kweon, 2001^113^ lamivudine, 100 mg/day, 52 weeks | Placebo, 52 weeks
Kweon, 2001^113^ lamivudine, 100 mg/day, 52 weeks | Placebo, 52 weeks | 47/33 | 52/52 | HAI score: Periportal inflammation | 2±1 | 3±1 | -0.64 (-1.10; -0.19)
Kweon, 2001^113^ lamivudine, 100 mg/day, 52 weeks | Placebo, 52 weeks
Kweon, 2001^113^ lamivudine, 100 mg/day, 52 weeks | Placebo, 52 weeks | 47/33 | 52/52 | Population of activated hepatic stellate cells and collagen synthesis as measured by immunohistochemistry for a-SMA | 1±0 | 1±0 | -4.66 (-5.51; -3.80)
47/33 | 52/52 | HAI score: lobular necrosis | 1±1 | 2±1 | -0.46 (-0.91; -0.01)
47/33 | 52/52 | Total Knodell score | 7±3 | 10±3 | -0.81 (-1.27; -0.34)
47/33 | 52/52 | HAI score: fibrosis | 2±1 | 2±1 | -0.39 (-0.84; 0.06)
47/33 | 52/52 | HBV DNA (pg/ml) | 33±120 | 71±111 | -0.32 (-0.77; 0.12)
Hadziyannis, 2003^41^ Adefovir dipivoxil, 10 mg daily, 48 weeks | Placebo, 48 weeks | 123/61 | 48/48 | Change in Knodell necroinflammatory score | -3±3 | 0±3 | -1.23 (-1.56; -0.90)
Hadziyannis, 2003^41^ Adefovir dipivoxil, 10 mg daily, 48 weeks | Placebo, 48 weeks
123/61 | 48/48 | Change in total Knodell score | -4±3 | 0±4 | -1.24 (-1.57; -0.91)
123/61 | 48/48 | Change in Knodell fibrosis score | 0±1 | 0±1 | -0.52 (-0.83; -0.21)
Marcellin, 2003^42^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Adefovir dipivoxil, 30 mg/day, 48 weeks | 171/173 | 48/48 | Change in ALT | -92±167 | -74±128 | -0.12 (-0.33; 0.09)
Placebo, 48 weeks | 171/167 | 48/48 | Change in ALT | -92±167 | -23±141 | -0.45 (-0.66; -0.23)
Marcellin, 2003^42^ Adefovir dipivoxil, 30 mg/day, 48 weeks | Placebo, 48 weeks | 173/167 | 48/48 | Change in ALT | -74±128 | -23±141 | -0.38 (-0.60; -0.17)
Marcellin, 2003^42^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Adefovir dipivoxil, 30 mg/day, 48 weeks | 171/173 | 48/48 | Change in Knodell necroinflammatory activity scores | -3±3 | -3±3 | 0.18 (-0.03; 0.39)
Placebo, 48 weeks | 171/167 | 48/48 | Change in Knodell necroinflammatory activity scores | -3±3 | 0±3 | -0.77 (-0.99; -0.55)
Marcellin, 2003^42^ Adefovir dipivoxil, 30 mg/day, 48 weeks | Placebo, 48 weeks | 173/167 | 48/48 | Change in Knodell necroinflammatory activity scores | -3±3 | 0±3 | -0.95 (-1.17; -0.72)
Marcellin, 2003^42^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Adefovir dipivoxil, 30 mg/day, 48 weeks | 171/173 | 48/48 | Change in Knodell fibrosis scores | 0±1 | 0±1 | 0.17 (-0.04; 0.38)
Placebo, 48 weeks | 171/167 | 48/48 | Change in Knodell fibrosis scores | 0±1 | 0±1 | -0.20 (-0.41; 0.01)
Marcellin, 2003^42^ Adefovir dipivoxil, 30 mg/day, 48 weeks | Placebo, 48 weeks | 173/167 | 48/48 | Change in Knodell fibrosis scores | 0±1 | 0±1 | -0.37 (-0.59; -0.16)
Marcellin, 2003^42^ Adefovir dipivoxil, 10 mg/day, 48 weeks | Adefovir dipivoxil, 30 mg/day, 48 weeks | 171/173 | 48/48 | Change in serum HBV DNA log copies/ml | -4±2 | -4±2 | 0.54 (0.32; 0.76)
Placebo, 48 weeks | 171/167 | 48/48 | Change in serum HBV DNA log copies/ml | -4±2 | -1±1 | -1.74 (-1.99; -1.49)
Marcellin, 2003^42^ Adefovir dipivoxil, 30 mg/day, 48 weeks | Placebo, 48 weeks | 173/167 | 48/48 | Change in serum HBV DNA log copies/ml | -4±2 | -1±1 | -2.34 (-2.62; -2.07)
Perrillo, 2004^58^ Adefovir dipivoxil, 10 mg/day for 52 weeks Lamivudine, 100mg/day for at least 6 months, 52 weeks | Lamivudine, 100 mg/day, 52 weeks | 46/49 | 52/52 | Change from baseline in ALT level (IU/L) | -90±160 | -44±132 | -0.31 (-0.72; 0.09)
Perrillo, 2004^58^ Adefovir dipivoxil, 10 mg/day for 52 weeks Lamivudine, 100mg/day for at least 6 months, 52 weeks | Lamivudine, 100 mg/day, 52 weeks
46/49 | 52/52 | Median HBV DNA level at baseline, log10 copies/mL | 9±1 | 9±1 | 0.38 (-0.02; 0.79)
46/49 | 52/52 | Median change from baseline in HBV DNA level | -5±2 | 0±4 | -1.63 (-2.10; -1.17)
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day, 48 weeks | Lamivudine, 100 mg/day, 48 weeks | 20/19 | 48/48 | Change in serum ALT level | -49±82 | 0±31 | -0.78 (-1.43; -0.12)
Adefovir dipivoxil, 10 mg/day, 48 weeks | 20/19 | 48/48 | Change in serum ALT level | -49±82 | -88±122 | 0.38 (-0.26; 1.01)
Peters, 2004^43^ Lamivudine, 100 mg/day, 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | 19/19 | 48/48 | Change in serum ALT level | 0±31 | -88±122 | 0.99 (0.31; 1.66)
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day, 48 weeks | Lamivudine, 100 mg/day, 48 weeks | 20/19 | 16/16 | Time-weighted average change from baseline in serum HBV DNA level | -2±1 | | -5.51 (-6.91; -4.11)
Adefovir dipivoxil, 10 mg/day, 48 weeks | 20/19 | 16/16 | Time-weighted average change from baseline in serum HBV DNA level | -2±1 | -3±1 | 0.24 (-0.39; 0.87)
Peters, 2004^43^ Lamivudine, 100 mg/day, 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | 19/19 | 16/16 | Time-weighted average change from baseline in serum HBV DNA level | | -3±1 | 4.33 (3.14; 5.51)
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day, 48 weeks | Lamivudine, 100 mg/day, 48 weeks | 20/19 | 48/48 | Time-weighted average change from baseline in serum HBV DNA level | -3±1 | | -5.42 (-6.80; -4.03)
Adefovir dipivoxil, 10 mg/day, 48 weeks | 20/19 | 48/48 | Time-weighted average change from baseline in serum HBV DNA level | -3±1 | -3±1 | 0.33 (-0.30; 0.96)
Peters, 2004^43^ Lamivudine, 100 mg/day, 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | 19/19 | 48/48 | Time-weighted average change from baseline in serum HBV DNA level | | -3±1 | 4.14 (2.99; 5.29)
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day, 48 weeks | lamivudine, 100 mg/day, 48 weeks | 20/19 | 16/16 | Change in serum HBV DNA log10 copies | -3±1 | 0±0 | -5.92 (-7.41; -4.43)
Adefovir dipivoxil, 10 mg/day, 48 weeks | 20/19 | 16/16 | Change in serum HBV DNA log10 copies | -3±1 | -3±1 | 0.20 (-0.43; 0.83)
Peters, 2004^43^ Lamivudine, 100 mg/day, 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | 19/19 | 16/16 | Change in serum HBV DNA log10 copies | | -3±1 | 4.48 (3.27; 5.70)
Peters, 2004^43^ Adefovir dipivoxil, 10 mg/day Lamivudine, 100mg/day, 48 weeks | Lamivudine, 100 mg/day, 48 weeks | 20/19 | 48/48 | Change in serum HBV DNA log 10 copies | -3±1 | 0±1 | -3.09 (-4.03; -2.14)
Adefovir dipivoxil, 10 mg/day, 48 weeks | 20/19 | 48/48 | Change in serum HBV DNA log 10 copies | -3±1 | -4±1 | 0.43 (-0.21; 1.06)
Peters, 2004^43^ Lamivudine, 100 mg/day, 48 weeks | Adefovir dipivoxil, 10 mg/day, 48 weeks | 19/19 | 48/48 | Change in serum HBV DNA log10 copies | 0±1 | -4±1 | 3.09 (2.13; 4.05)
Marcellin, 2004^57^ Lamivudine (Epivir-HBV or Zeffix, GlaxoSmithKline), 100 mg once daily, 48 weeks | 48 weeks | 181/181 | 48/48 | Change from baseline in HBV DNA after LAM log copies/ml | | | -4.20 (-4.50; -3.90)
48 weeks | 181/181 | 72/72 | Change in HBV DNA in log copies/ml from baseline after LAM | | | -1.60 (-1.20; -2.00)
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10 mg daily continued-adefovir therapy for the previous treatment for 48 weeks, 96 weeks | Placebo after 48 weeks of adefovir therapy, 96 weeks | 80/40 | 96/96 | Change in serum ALT, IU/liter | -98±118 | -63±131 | -0.29 (-0.67; 0.10)
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10 mg daily continued-adefovir therapy for the previous treatment for 48 weeks, 96 weeks
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10 mg daily continued-adefovir therapy for the previous treatment for 48 weeks, 96 weeks | Adefovir dipivoxil, 10 mg daily after 48 weeks of placebo therapy, 96 weeks | 80/60 | 96/96 | Change in serum ALT, IU/liter | -98±118 | -130±213 | 0.19 (-0.14; 0.53)
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10 mg daily continued-adefovir therapy for the previous treatment for 48 weeks, 96 weeks
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10 mg daily continued-adefovir therapy for the previous treatment for 48 weeks, 96 weeks | Placebo after 48 weeks of adefovir therapy, 96 weeks | 80/40 | 114/96 | Change in serum ALT, IU/liter | -97±120 | -63±131 | -0.27 (-0.66; 0.11)
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10 mg daily continued-adefovir therapy for the previous treatment for 48 weeks, 96 weeks
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10 mg daily continued-adefovir therapy for the previous treatment for 48 weeks, 96 weeks | Adefovir dipivoxil, 10 mg daily after 48 weeks of placebo therapy, 96 weeks | 80/60 | 114/96 | Change in serum ALT, IU/liter | -97±120 | -130±213 | 0.20 (-0.14; 0.53)
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10 mg daily continued-adefovir therapy for the previous treatment for 48 weeks, 96 weeks
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10 mg daily continued-adefovir therapy for the previous treatment for 48 weeks, 96 weeks | Placebo after 48 weeks of adefovir therapy, 96 weeks | 80/40 | 96/96 | Change in Knodell inflammatory scores | -4±3 | -1±2 | -1.37 (-1.78; -0.95)
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10 mg daily continued-adefovir therapy for the previous treatment for 48 weeks, 96 weeks
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10 mg daily continued-adefovir therapy for the previous treatment for 48 weeks, 96 weeks | Adefovir dipivoxil, 10 mg daily after 48 weeks of placebo therapy, 96 weeks | 80/60 | 96/96 | Change in Knodell inflammatory scores | -4±3 | -2±4 | -0.61 (-0.95; -0.27)
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10 mg daily continued-adefovir therapy for the previous treatment for 48 weeks, 96 weeks
Hadziyannis, 2005^98^ Adefovir dipivoxil, 10 mg daily continued-adefovir therapy for the previous treatment for 48 weeks, 96 weeks | Placebo after 48 weeks of adefovir therapy, 96 weeks | 80/40 | 96/96 | Change in Knodell scores | -5±3 | -1±2 | -1.34 (-1.75; -0.92)
Adefovir dipivoxil, 10 mg daily after 48 weeks of placebo therapy, 96 weeks | 80/60 | 96/96 | Change in Knodell scores | -5±3 | -2±5 | -0.62 (-0.96; -0.27)
Placebo after 48 weeks of adefovir therapy, 96 weeks | 80/40 | 96/96 | Change in Knodell fibrosis scores | 0±1 | 0±1 | 0.09 (-0.29; 0.47)
Adefovir dipivoxil, 10 mg daily after 48 weeks of placebo therapy, 96 weeks | 80/60 | 96/96 | Change in Knodell fibrosis scores | 0±1 | 0±1 | -0.21 (-0.55; 0.12)
Placebo after 48 weeks of adefovir therapy, 96 weeks | 80/40 | 96/96 | Change in serum HBV DNA level in log copies/ml | -3±1 | -1±1 | -1.67 (-2.11; -1.24)
Adefovir dipivoxil, 10 mg daily after 48 weeks of placebo therapy, 96 weeks | 80/60 | 96/96 | Change in serum HBV DNA level in log copies/ml | -3±1 | -4±1 | 0.32 (-0.02; 0.66)
Placebo after 48 weeks of adefovir therapy, 96 weeks | 80/40 | 114/96 | Change in serum HBV DNA level— log copies/ml | -3±1 | -1±1 | -1.65 (-2.08; -1.22)
Adefovir dipivoxil, 10 mg daily after 48 weeks of placebo therapy, 96 weeks | 80/60 | 114/96 | Change in serum HBV DNA level in log copies/ml | -3±1 | -4±1 | 0.25 (-0.09; 0.58)
Lau, 2005^56^ Lamivudine (Epivir-HBV or Zeffix, Glaxo-SmithKline), 100 mg/day, 48 weeks | Baseline, baseline, 48 weeks | 271/272 | 48/48 | Reduction in HBV DNA log copies/ml | | | -5.80 (-5.40; -6.10)
271/272 | 72/72 | Reduction in HBV DNA log copies/ml | | | -1.90 (-1.50; -2.30)
Lai, 2005^72^ Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 500 mg/day (both 400mg or 600 mg/day) Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100mg/day, 52 weeks | Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day, 52 weeks | 41/19 | 52/52 | Mean change in HBV DNA levels from baseline (log 10 copies/mL) | -6±2 | -5±3 | -0.59 (-1.14; -0.03)
Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 500 mg/day, 52 weeks | 41/44 | 52/52 | Mean change in HBV DNA levels from baseline (log 10 copies/mL) | -6±2 | -6±2 | 0.01 (-0.42; 0.43)
Lai, 2005 ^72^ Lamivudine GlaxoSmithKline (Research Triangle Park, NC), 100 mg/day, 52 weeks | Telbivudine Idenix Pharmaceuticals Inc (Cambridge, MA), 500 mg/day, 52 weeks | 19/44 | 52/52 | Mean change in HBV DNA levels from baseline (log 10 copies/mL) | -5±3 | -6±2 | 0.62 (0.07; 1.17)
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks | 42/47 | 24/24 | Reduction in HBV DNA by Roche PCR assay, (log 10 copies/mL | -4±2 | -4±2 | -0.24 (-0.66; 0.17)
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks
Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | 42/47 | 24/24 | Reduction in HBV DNA by Roche PCR assay, (log 10 copies/mL | -4±2 | -2±2 | -1.39 (-1.86; -0.93)
Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, 48 weeks | 42/45 | 24/24 | Reduction in HBV DNA by Roche PCR assay, (log 10 copies/mL | -4±2 | -1±2 | -1.94 (-2.45; -1.43)
Chang, 2005^76^ Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, 48 weeks | 47/47 | 24/24 | Reduction in HBV DNA by Roche PCR assay, (log 10 copies/mL | -4±2 | -2±2 | -1.00 (-1.43; -0.57)
Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, 48 weeks | 47/45 | 24/24 | Reduction in HBV DNA by Roche PCR assay, (log 10 copies/mL | -4±2 | -1±2 | -1.49 (-1.95; -1.03)
Chang, 2005^76^ Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, 48 weeks | 47/45 | 24/24 | Reduction in HBV DNA by Roche PCR assay, (log 10 copies/mL | -2±2 | -1±2 | -0.57 (-0.98; -0.15)
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, 48 weeks | 42/47 | 48/48 | Reduction in HBV DNA by Roche PCR assay, (log 10 copies/mL | -5±2 | -4±2 | -0.31 (-0.73; 0.11)
Chang, 2005^76^ Entecavir, 1 mg/day after at least 24 weeks of lamivudine, total 48 weeks
Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, 48 weeks | 42/47 | 48/48 | Reduction in HBV DNA by Roche PCR assay, (log 10 copies/mL | -5±2 | -3±2 | -1.24 (-1.69; -0.78)
Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, 48 weeks | 42/45 | 48/48 | Reduction in HBV DNA by Roche PCR assay, (log10 copies/mL | -5±2 | -1±3 | -1.59 (-2.08; -1.11)
Chang, 2005^76^ Entecavir, 0.5 mg/day after at least 24 weeks of lamivudine, 48 weeks | Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, total 48 weeks | 47/47 | 48/48 | Reduction in HBV DNA by Roche PCR assay,(log10 copies/mL | -4±2 | -3±2 | -0.78 (-1.20; -0.36)
Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, 48 weeks | 47/45 | 48/48 | Reduction in HBV DNA by Roche PCR assay, (log 10 copies/mL | -4±2 | -1±3 | -1.23 (-1.67; -0.78)
Chang, 2005^76^ Entecavir, 0.1 mg/day after at least 24 weeks of lamivudine, 48 weeks | Lamivudine, 100 mg/day after at least 24 weeks of lamivudine, 48 weeks | 47/45 | 48/48 | Reduction in HBV DNA by Roche PCR assay, (log 10 copies/mL | -3±2 | -1±3 | -0.62 (-1.04; -0.20)
Chang, 2006^73^ Entecavir (Baraclude, Bristol-Myers Squibb), 0.5 mg/day, 52 weeks | Lamivudine (Epivir-HBV, GlaxoSmithKline), 100 mg/day, 52 weeks | 354/355 | 52/52 | Mean change in HBV DNA from baseline by PCR assay in log copies/ml | -7±2 | -5±3 | -0.65 (-0.80; -0.50)
Lai, 2006^74^ Entecavir (Baraclude, Bristol-Myers Squibb), 0.5 mg/day, 52 weeks | Lamivudine (Epivir-HBV, GlaxoSmithKline), 100 mg/day, 52 weeks | 325/313 | 52/52 | Mean change in HBV DNA level from baseline by PCR assay in log copies/ml | -5±2 | -4±2 | -0.28 (-0.43; -0.12)
Sherman, 2006^75^ Entecavir, 1 mg/day, 63 weeks | Lamivudine, 100, 52 weeks | 141/145 | 63/52 | Mean change HBV DNA from baseline by PCR assay, log10 copies/mL | -5±2 | 0±2 | -2.20 (-2.49; -1.91)
Chan, 2007^44^ telbivudine Idenix Pharmaceuticals, Cambridge, MA, 600 mg/day in 3 tablets, 24 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 24 weeks | 45/91 | 52/52 | Adjusted for baseline covariates (baseline HBV DNA level, age, body mass index, sex, and study site) Mean HBV DNA, log 10 copies/mL | | | -0.84 (-1.49; -0.19)
Chan, 2007^44^ telbivudine Idenix Pharmaceuticals, Cambridge, MA, 600 mg/day in 3 tablets, 24 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 24 weeks
Chan, 2007^44^ telbivudine Idenix Pharmaceuticals, Cambridge, MA, 600 mg/day in 3 tablets, 24 weeks | Adefovir (Hepsera, Gilead Sciences, Foster City, CA), 10 mg/day, 24 weeks | 45/91 | 24/24 | Change from baseline in mean HBV DNA, log 10 copies/mL | -6±1 | -5±2 | -0.73 (-1.09; -0.36)
45/91 | 24/24 | Change from baseline in mean HBV DNA, log 10 copies/mL adjusted for baseline covariates (baseline HBV DNA level, age, body mass index, sex, and study site) | | | -1.46 (-2.01; -0.91)
45/91 | 52/52 | Adjusted for baseline covariates (baseline HBV DNA level, age, body mass index, sex, and study site) Change from baseline in mean HBV DNA, log10 copies/mL | | | -0.84 (-1.49; -0.19)
Lai, 1998^50^ Lamivudine, 25 mg/day, 48 weeks | Lamivudine, 100 mg/day, 48 weeks | 142/143 | 48/48 | Knodell score | 6±3 | 5±3 | 0.33 (0.10; 0.57)
Placebo, 48 weeks | 142/73 | 48/48 | Knodell score | 6±3 | 8±4 | -0.59 (-0.88; -0.31)
Lai, 1998^50^ Lamivudine, 100 mg/day, 48 weeks | Placebo, 48 weeks | 143/73 | 48/48 | Knodell score | 5±3 | 8±4 | -0.89 (-1.18; -0.60)

Table E7 Number of subjects experiencing adverse events from RCTs

Adverse Event | Number of Studies | Treatment n / N (%) | Control n / N (%) | Absolute Risk Difference [95% CI] | Relative Risk Ratio [95% CI] | Trial(s) Duration
(A) Adefovir monotherapy ([underlined: L-nucleotide analogue])
Versus placebo ^41,^ ^42^
Subjects not completing study/treatment | | 26 / 345* (7.5) (10 and 30 mg) | 13 / 170* (7.6) | 0 [-5; 5] | 0.99 [0.52; 1.87] | 48 weeks
Any adverse event | 1 | 94 / 123 (76.4) | 45 / 61 (73.7) | 3 [-11; 16] | 1.04 [0.87; 1.24] | 48 weeks
Severe adverse event (grade III or IV) | 2 | 24 / 294 (8.2) | 19 / 228 (8.3) | 0 [-6; 6] | 0.95 [0.45; 2.01]
AE leading to discontinuation of study drug | 2 | 4 / 294 (1.4) | 1 / 228 (<1) | 1 [-1; 3] | 2.34 [0.37; 14.75]
Treatment-related adverse events for 10 mg dose (Gilead Sciences package insert)
Asthenia | 2 | 38 / 294 (12.9) | 32 / 228 (14.0) | -1 [-7; 5] | 0.92 [0.59; 1.43] | 48 weeks
Headache | 2 | 26 / 294 (8.8) | 23 / 228 (10.1) | -1 [-6; 4] | 0.88 [0.51; 1.49] | 48 weeks
Abdominal pain | 2 | 26 / 294 (8.8) | 25 / 228 (11.0) | -2 [-7; 3] | 0.81 [0.48; 1.36] | 48 weeks
Nausea | 2 | 15 / 294 (5.1) | 18 / 228 (7.9) | -3 [-7; 2] | 0.65 [0.33; 1.25] | 48 weeks
Flatulence | 2 | 12 / 294 (4.1) | 9 / 228 (3.9) | 0 [-3; 4] | 1.03 [0.44; 2.41] | 48 weeks
Diarrhea | 2 | 9 / 294 (3.1) | 9 / 228 (3.9) | -1 [-4; 2] | 0.78 [0.31; 1.92] | 48 weeks
Dyspepsia | 2 | 12 / 294 (4.1) | 5 / 228 (2.2) | 1 [-2; 4] | 1.40 [0.47; 4.11]
Other adverse events
Pharyngitis | 2 | 67 / 294 (22.8) | 68 / 228 (29.8) | -6 [-13; 2] | 0.80 [0.60; 1.07] | 48 weeks
Flu-like syndrome | 2 | 41 / 294 (13.9) | 44 / 228 (19.3) | -5 [-14; 3] | 0.70 [0.41; 1.22] | 48 weeks
Back pain | 2 | 23 / 294 (7.8) | 15 / 228 (6.6) | 1 [-4; 5] | 1.13 [0.59; 2.17]
Versus lamivudine, subjects with lamivudine resistance ^43^
Subjects not completing study/treatment | 1 | 1 / 20** (5) | 1 / 19 (5.3) | 0 [-14; 14] | 0.95 [0.06; 14.13] | 48 weeks
Any adverse event | 1 | 18 / 19 (94.7) | 19 / 19 (100) | -5 [-19; 8] | 0.95 [0.82; 1.09] | 48 weeks
Serious adverse event | 1 | 3 / 19 (15.8) | 1 / 19 (5.3) | 11 [-9; 30] | 3.0 [0.34; 26.3] | 48 weeks
AE leading to discontinuation of study drug | 1 | 0 / 19 | 0 / 19 | 0 | - | 48 weeks
Asthenia | 1 | 9 / 19 (47.4) | 6 / 19 (31.6) | 16 [-15; 46] | 1.50 [0.66; 3.39] | 48 weeks
Headache | 1 | 5 / 19 (26.3) | 5 / 19 (26.3) | 0 | 1.00 [0.35; 2.90] | 48 weeks
Abdominal pain | 1 | 4 / 19 (21) | 5 / 19 (26.3) | -5 [-32; 22] | 0.80 [0.25; 2.53] | 48 weeks
Diarrhea | 1 | 2 / 19 (10.5) | 6 / 19 (31.6) | -21 [-46; 4] | 0.33 [0.08; 1.45] | 48 weeks
Pharyngitis | | 5 / 19 (26.3) | 6 / 19 (31.6) | -5 [-34; 24] | 0.83 [0.31; 2.27]
Versus telbivudine ^44^
Subjects not completing study/treatment | 1 | 2 / 45 (4.4) | 2 / 45 (4.4) | 0 [-9; 9] | 1.00 [0.13; 7.43] | 52 weeks
Any adverse event | 1 | 27 / 44 (61.4) | 34 / 45 (75.6) | -14 [-33; 5] | 0.81 [0.61; 1.08] | 52 weeks
Serious adverse event | 1 | NR | NR | - | - | 52 weeks
AE leading to discontinuation of study drug | 1 | 0 / 44 | 0 / 45 | 0 | - | 52 weeks
Upper respiratory tract infection | 1 | 5 / 44 (11.4) | 5 / 45 (11.1) | 0 [-13; 13] | 1.02 [0.32; 3.29] | 52 weeks
Headache | 1 | 3 / 44 (6.8) | 5 / 45 (11.1) | -4 [-16; 8] | 0.61 [0.16; 2.41] | 52 weeks
Diarrhea | 1 | 1 / 44 (2.3) | 6 / 45 (13.3) | -11 [-22; 0] | 0.17 [0.02; 1.36] | 52 weeks
Pharyngitis | 1 | 5 / 44 (11.4) | 1 / 45 (2.2) | 9 [-1; 19] | 5.11 [0.62; 42.03] | 52 weeks
Influenza | 1 | 3 / 44 (6.8) | 5 / 45 (11.1) | -4 [-16; 8] | 0.61 [0.16; 2.41] | 52 weeks
Back pain | | 3 / 44 (6.8) | 6 / 45 (13.3) | -7 [-19; 6] | 0.51 [0.14; 1.92]
Versus adefovir, then switched to telbivudine ^44^
Subjects not completing study/treatment | 1 | 2 / 45 (4.4) | 0 / 46 | 4 [-3; 12] | 5.34 [0.25; 114.49] | 52 weeks
Any adverse event | 1 | 27 / 44 (61.4) | 31 / 46 (67.4) | -6 [-26; 14] | 0.91 [0.67; 1.24] | 52 weeks
Serious adverse event | 1 | NR | NR | | | 52 weeks
AE leading to discontinuation of study drug | 1 | 0 / 44 | 0 / 46 | 0 | - | 52 weeks
Upper respiratory tract infection | 1 | 5 / 44 (11.4) | 6 / 46 (13) | -2 [-15; 12] | 0.87 [0.29; 2.65] | 52 weeks
Headache | 1 | 3 / 44 (6.8) | 6 / 46 (13) | -6 [-18; 6] | 0.52 [0.14; 1.96] | 52 weeks
Diarrhea | 1 | 1 / 44 (2.3) | 5 / 46 (10.9) | -9 [-19; 1] | 0.21 [0.03; 1.72] | 52 weeks
Pharyngitis | 1 | 5 / 44 (11.4) | 2 / 46 (4.3) | 7 [-4; 18] | 2.61 [0.53; 12.78] | 52 weeks
Influenza | 1 | 3 / 44 (6.8) | 4 / 46 (8.7) | -2 [-13; 9] | 0.78 [0.19; 3.31] | 52 weeks
Back pain | 1 | 3 / 44 (6.8) | 3 / 46 (6.5) | 0 [-10; 11] | 1.05 [0.22; 4.91]
* Includes subjects not receiving any study medication
** Includes 1 subject not receiving any study medication
(B) Adefovir versus combination therapy
Versus combined lamivudine and adefovir ^43^
Subjects not completing study/ treatment | 1 | 1 / 20* (5) | 0 / 20 | 5 [-8; 18] | 3.00 [0.13; 69.52] | 48 weeks
Any adverse event | 1 | 18 / 19 (94.7) | 18 / 20 (90) | 5 [-12; 21] | 1.05 [0.88; 1.26] | 48 weeks
| | | | | | 48 weeks
Serious adverse event | 1 | 3 / 19 (15.8) | 0 / 20 | 16 [-2; 34] | 7.35 [0.40; 133.48} | 48 weeks
| | | | | | 48 weeks
AE leading to discontinuation of study drug | 1 | 0 / 19 | 0 / 20 | - | - | 48 weeks
| | | | | | 48 weeks
Asthenia | 1 | 9 / 19 (47.4) | 10 / 20 (50) | -3 [-34; 29] | 0.95 [0.50; 1.81]
Headache | 1 | 5 / 19 (26.3) | 6 / 20 (30) | -4 [-32; 25] | 0.88 [0.32; 2.40]
Abdominal pain | 1 | 4 / 19 (21) | 6 / 20 (30) | -9 [-36; 18] | 0.70 [0.23; 2.10]
Diarrhea | 1 | 2 / 19 (10.5) | 2 / 20 (10) | 1 [-19; 20] | 1.05 [0.16; 6.74]
Pharyngitis | 1 | 5 / 19 (26.3) | 1 / 20 (5) | 21 [-1; 43] | 5.26 [0.68; 41.01]
* Includes 1 subject not receiving any study medication
(C) Lamivudine monotherapy ([underlined: L-nucleoside analog])
Versus placebo ^46,^ ^48,^ ^50^
Subjects not completing study/treatment | 2 | 33 / 374 (8.8) | 16 / 120 (13.3) | -1 [-7; 4] | 0.87 [0.51; 1.49] | 52–104 weeks
Any adverse event | 1 | 224 / 285 (78.6) | 56 / 73 (76.7) | 2 [-9; 13] | 1.02 [0.89; 1.18] | 52 weeks
Serious adverse event | 2 | 18 / 374 (4.8) | 6 / 120 (5) | 2 [-1; 4] | 1.24 [0.53; 2.93] | 52–104 weeks
Upper respiratory tract infection | 1 | 100 / 285 (35.1) | 21 / 73 (28.8) | 6 [-5; 18] | 1.22 [0.82; 1.81] | 52 weeks
Upper respiratory tract symptoms | 1 | 29 / 89 (32.6) | 15 / 47 (31.9) | 1 [-16; 17] | 1.02 [0.28; 1.81] | 104 weeks
Asthenia | 2 | 49 / 355 (13.8) | 28 / 144 (19.4) | -5 [-12; 3] | 0.76 [0.49; 1.17] | 52–68 weeks
Headache | 3 | 57 / 444 (12.8) | 23 / 191 (12) | -1 [-6; 5] | 0.88 [0.56; 1.39] | 52–104 weeks
Abdominal pain | 1 | 45 / 285 (15.8) | 9 / 73 (12.3) | 3 [-5; 12] | 0.95 [0.71; 1.28] | 52 weeks
Diarrhea | 1 | 44 / 285 (15.4) | 7 / 73 (9.6) | 6 [-2; 14] | 1.61 [0.76; 3.43] | 52 weeks
Nausea | 2 | 21 / 355 (5.9) | 12 / 144 (8.3) | -1 [-15; 13] | 1.20 [0.17; 8.32] | 52–68 weeks
Pyrexia | 1 | 18 / 285 (6.3) | 2 / 73 (2.7) | 4 [-1; 8] | 2.31 [0.55; 9.71] | 52 weeks
Myalgia | 1 | 0 / 71 | 6 / 70 (8.6) | -9 [-16; -2] | 0.08 [0.00; 1.32] | 68 weeks
Versus placebo, subjects refractory interferon therapy ^47^
Subjects not completing study/treatment | 1 | 9 / 119 (7.6) | 10 / 56 (17.9) | -10 [-21; 1] | 0.42 [0.18; 0.98] | 68 weeks
AE leading to discontinuation of study drug | 1 | 1 / 119 (<1) | 4 / 56 (7.1) | -6 [-13; 1] | 0.12 [0.01; 1.03] | 68 weeks
Asthenia | 1 | 18 / 119 (15.1) | 10 / 56 (17.9) | -3 [-15; 9] | 0.85 [0.42; 1.71] | 68 weeks
Headache | 1 | 10 / 119 (8.4) | 7 / 56 (12.5) | -4 [-14; 6] | 0.67 [0.27; 1.67] | 68 weeks
Diarrhea | 1 | 8 / 119 (6.7) | 0 / 56 | 7 [2; 12] | 8.08 [0.47; 137.48] | 68 weeks
Nausea | 1 | 12 / 119 (10.1) | 6 / 56 (10.7) | -1 [-10; 9] | 0.94 [0.37; 2.38] | 68 weeks
Pyrexia | 1 | 6 / 119 (5) | 0 / 56 | 5 [0; 10] | 6.18 [0.35; 107.73] | 68 weeks
Myalgia | 1 | 13 / 119 (10.9) | 3 / 56 (5.4) | 6 [-3; 14] | 2.04 [0.61; 6.87]
Versus placebo, subjects with advanced liver disease ^51^
Any adverse event | 1 | 335 / 436 (76.8) | 178 / 215 (82.8) | -6 [-12; 0] | 0.93 [0.86; 1.01] | 32 months (median)
Serious adverse event | 1 | 54 / 436 (12.4) | 38 / 215 (17.7) | -5 [-11; 1] | 0.70 [0.48; 1.03] | 32 months (median)
AE leading to discontinuation of study drug | | NR | NR | - | - | 32 months (median)
Ear, nose, throat infections | 1 | 97 / 436 (22.2) | 44 / 215 (20.5) | 2 [-5; 8] | 1.09 [0.79; 1.49] | 32 months (median)
Asthenia | 1 | 65 / 436 (14.9) | 42 / 215 (19.5) | -5 [-11; 2] | 0.76 [0.54; 1.09] | 32 months (median)
Headache | 1 | 64 / 436 (14.7) | 21 / 215 (9.8) | 5 [0; 10] | 1.50 [0.94; 2.39] | 32 months (median)
Abdominal pain | 1 | 77 / 436 (17.7) | 43 / 215 (20.0) | -2 [-9; 4] | 0.88 [0.63; 1.24] | 32 months (median)
Diarrhea | 1 | 33 / 436 (7.6) | 29 / 215 (13.5) | -6 [-11; -1] | 0.56 [0.35; 0.90] | 32 months (median)
Cough | 1 | 62 / 436 (14.2) | 15 / 215 (7.0) | 7 [3; 12] | 2.04 [1.19; 3.50]
Versus placebo, HBV antigen-negative/ pHBV DNA-positive (precore mutant) patient ^49^
Any adverse event | 1 | 40 / 65 (61.5) | 28 / 60 (46.7) | 15 [-2 to 32] | 1.32 [0.95 to 1.84] | 26 weeks
Headache | 1 | 12 / 65 (18.5) | 10 / 60 (16.7) | 2 [-12 to 15] | 1.11 [0.52 to 2.37] | 26 weeks
Asthenia | 1 | 8 / 65 (12.3) | 8 / 60 (13.3) | -1 [-13 to 11] | 0.92 [0.37 to 2.30] | 26 weeks
Abdominal pain | 1 | 8 / 65 (12.3) | 4 / 60 (6.7) | 6 [-5 to 16] | 1.85 [0.59 to 5.82]
Versus entecavir (see below)
Versus telbivudine (see below)
Versus pegylated interferon-α-2a monotherapy ^56,^ ^57^
Subjects not completing treatment/study | 2 | 71 / 456* (15.6) | 45 / 453* (9.9) | 6 [1; 10] | 1.57 [1.10; 2.22] | 72 weeks
Any adverse event | 2 | 238 / 453 (52.5) | 395 / 448 (88.2) | -36 [-43; -29] | 0.59 [0.51; 0.69] | 72 weeks
Serious adverse event | 2 | 10 / 453 (2.2) | 21 / 448 (4.7) | -2 [-5; 0] | 0.47 [0.22; 0.99] | 72 weeks
AE leading to discontinuation of study drug | 2 | 2 / 453 (<1) | 21 / 448 (4.7) | -5 [-10; 1] | 0.13 [0.20; 0.90] | 72 weeks
Dose modification due to AE | 2 | 0 / 453 | 33 / 448 (7.4) | -7 [-10; -5] | 0.03 [0.00; 0.22] | 72 weeks
Pyrexia | 2 | 20 / 453 (4.4) | 238 / 448 (53.1) | -50 [-60; -40] | 0.08 [0.05; 0.13] | 72 weeks
Fatigue | 2 | 70 / 453 (15.5) | 182 / 448 (40.6) | -25 [-31; -20] | 0.38 [0.30; 0.49] | 72 weeks
Myalgia | 2 | 19 / 453 (4.2) | 117 / 448 (26.1) | -22 [-26; -18] | 0.16 [0.08; 0.33] | 72 weeks
Headache | 2 | 41 / 453 (9.1) | 118 / 448 (26.3) | -17 [-22; -12] | 0.34 [0.25; 0.48] | 72 weeks
Alopecia | 2 | 7 / 453 (1.5) | 79 / 448 (17.6) | -16 [-21; -10] | 0.09 [0.04; 0.20] | 72 weeks
Decreased appetite | 2 | 11 / 453 (2.4) | 71 / 448 (15.8) | -13 [-17; -10] | 0.16 [0.08; 0.29] | 72 weeks
Dizziness | 2 | 19 / 453 (4.2) | 40 / 448 (8.9) | -5 [-8; -2] | 0.47 [0.28; 0.80] | 72 weeks
Diarrhea | 2 | 14 / 453 (3.1) | 45 / 448 (10.0) | -7 [-10; -4] | 0.31 [0.17; 0.56] | 72 weeks
Pruritus | 2 | 9 / 453 (2.0) | 35 / 448 (7.8) | -5 [-10; 0] | 0.27 [0.12; 0.59] | 72 weeks
Nausea | 2 | 15 / 453 (3.3) | 38 / 448 (8.5) | -5 [-9; -2] | 0.40 [0.16; 1.00] | 72 weeks
Arthralgia | 2 | 13 / 453 (2.9) | 51 / 448 (11.4) | -9 [-14; -3] | 0.25 [0.14; 0.46] | 72 weeks
Rigors | 2 | 0 / 453 | 29 / 448 (6.5) | -6 [-9; -4] | 0.03 [0.00; 0.25] | 72 weeks
Injection-site reaction | 2 | 0 / 453 | 34 / 448 (7.6) | -7 [-10; -4] | 0.03 [0.00; 0.22] | 72 weeks
| | | | | | 72 weeks
Gingival bleeding | 1 | 1 / 272 (<1) | 15 / 271 (5.5) | -5 [-8; -2] | 0.07 [0.01; 0.50]
Depression | 1 | 4 / 272 (1.5) | 13 / 271 (4.8) | -3 [-6; 0] | 0.31 [0.10; 0.93]
* Includes subjects not receiving any study medication
(D) Lamivudine versus combination therapy
Versus combined lamivudine and adefovir ^58^
Any adverse event | 1 | 40 / 48 (83.3) | 36 / 44 (81.8) | 2 [-14; 17] | 1.02 [0.84; 1.23] | 52 weeks
Versus combined pegylated interferon-α-2a and lamivudine ^56,^ ^57^
Subjects not completing treatment / study | 2 | 71 / 456* (15.6) | 49 / 457* (10.7) | 5 [1; 9] | 1.45 [1.03; 2.03] | 72 weeks
Any adverse event | 2 | 238 / 453 (52.5) | 395 / 450 (87.8) | -35 [-41; -29] | 0.60 [0.52; 0.68] | 72 weeks
Serious adverse event | 2 | 10 / 453 (2.2) | 28 / 450 (6.2) | -4 [-7; -1] | 0.36 [0.18; 0.73] | 72 weeks
AE leading to discontinuation of study drug | 2 | 2 / 453 (<1) | 19 / 450 (4.2) | -4 [-6; -2] | 0.13 [0.03; 0.47] | 72 weeks
Dose modification due to AE | 2 | 0 / 453 | 48 / 450 (10.7) | -10 [-15; -6] | 0.02 [0.00; 0.15] | 72 weeks
Pyrexia | 2 | 20 / 453 (4.4) | 246 / 450 (54.7) | -50 [-55; -45] | 0.08 [0.05; 0.12] | 72 weeks
Fatigue | 2 | 70 / 453 (15.5) | 176 / 450 (39.1) | -24 [-29; -18] | 0.40 [0.31; 0.51] | 72 weeks
Myalgia | 2 | 19 / 453 (4.2) | 126 / 450 (28.0) | -24 [-28; -19] | 0.15 [0.07; 0.33] | 72 weeks
Headache | 2 | 41 / 453 (9.1) | 115 / 450 (25.6) | -16 [-24; -7] | 0.35 [0.25; 0.49] | 72 weeks
Alopecia | 2 | 7 / 453 (1.5) | 98 / 450 (21.8) | -19 [-35; -2] | 0.07 [0.03; 0.15] | 72 weeks
Decreased appetite | 2 | 11 / 453 (2.4) | 60 / 450 (13.3) | -11 [-14; -7] | 0.19 [0.10; 0.35] | 72 weeks
Dizziness | 2 | 19 / 453 (4.2) | 44 / 450 (9.8) | -5[-11; 0] | 0.45[0.24; 0.84] | 72 weeks
Diarrhea | 2 | 14 / 453 (3.1) | 36 / 450 (8.0) | -5 [-8; -1] | 0.39 [0.21; 0.71] | 72 weeks
Pruritus | 2 | 9 / 453 (2.0) | 37 / 450 (8.2) | -6 [-10; -2] | 0.25 [0.12; 0.51] | 72 weeks
Nausea | 2 | 15 / 453 (3.3) | 40 / 450 (8.9) | -5 [-11; 0] | 0.39 [0.13; 1.20] | 72 weeks
Arthralgia | 2 | 13 / 453 (2.9) | 51 / 450 (11.3) | -9 [-14; -3] | 0.25 [0.14; 0.46] | 72 weeks
Rigors | 2 | 0 / 453 | 32 / 450 (7.1) | -6 [-14; 2] | 0.04 [0.01; 0.29] | 72 weeks
Injection-site reaction | 2 | 0 / 453 | 36 / 450 (8.0) | -8 [-15; -2] | 0.03 [0.00; 0.20] | 72 weeks
| | | | | | 72 weeks
Gingival bleeding | 1 | 1 / 272 (<1) | 15 / 271 (5.5) | -5 [-8; -2] | 0.07 [0.01; 0.50]
Depression | 1 | 4 / 272 (1.5) | 16 / 450 (5.9) | -4 [-8; -1] | 0.25 [0.08; 0.74]
Versus combined pegylated interferon-α-2b and lamivudine see below ^59^
Subjects not completing treatment/study | 1 | 2 / 50 | 2 / 50 (4) | 0 [-8; 8] | 1.00 [0.15; 6.82] | 52 weeks 76 weeks
Subjects not completing post-treatment followup | 1 | 13 / 50 | 7 / 50 (14) | 12 [-4; 28] | 1.86 [0.81; 4.26] | 52 weeks 76 weeks
| | | | | | 52 weeks 76 weeks
Serious adverse event | 1 | 0 / 50 | 4 / 50 (8) | -8 [-16; 0] | 0.11 [0.01; 2.01] | 52 weeks 76 weeks
| | | | | | 52 weeks 76 weeks
AE leading to discontinuation of study drug | 1 | 0 / 50 | 4 / 50 (8) | -8 [-16; 0] | 0.11 [0.01; 2.01] | 52 weeks 76 weeks
Upper respiratory tract symptoms | 1 | 19 / 50 (38) | 37 / 50 (74) | -36 [-54; -18] | 0.51 [0.35; 0.75] | 52 weeks 76 weeks
Pyrexia | 1 | 2 / 50 (4) | 36 / 50 (72) | -68 [-82; -54] | 0.06 [0.01; 0.22] | 52 weeks 76 weeks
Alopecia | 1 | 2 / 50 (4) | 24 / 50 (48) | -44 [-59; -29] | 0.08 [0.02; 0.33] | 52 weeks 76 weeks
Abdominal discomfort | 1 | 13 / 50 (26) | 22 / 50 (44) | -18 [-36; 0] | 0.59 [0.34; 1.04] | 52 weeks 76 weeks
Malaise | 1 | 7 / 50 (14) | 22 / 50 (44) | -30 [-47; -13] | 0.32 [0.15; 0.68] | 52 weeks 76 weeks
Headache | 1 | 2 / 50 (4) | 21 / 50 (42) | -38 [-53; -23] | 0.10 [0.02; 0.38] | 52 weeks 76 weeks
Myalgia | 1 | 2 / 50 (4) | 13 / 50 (26) | -22 [-35; -9] | 0.15[0.04; 0.65] | 52 weeks 76 weeks
Arthralgia | 1 | 2 / 50 (4) | 12 / 50 (24) | -20 [-33; -7] | 0.17 [0.04; 0.71] | 52 weeks 76 weeks
Decreased appetite | 1 | 0 / 50 | 12 / 50 (24) | -24 [-36; -12] | 0.04 [0.00; 0.66] | 52 weeks 76 weeks
Injection-site reaction | 1 | 0 / 50 | 12 / 50 (24) | -24 [-36; -12] | 0.04 [0.00; 0.66] | 52 weeks 76 weeks
Allergic rashes | 1 | 1 / 50 (2) | 9 / 50 (18) | -16 [-27; -5] | 0.11 [0.01; 0.84] | 52 weeks 76 weeks
Dizziness | 1 | 1 / 50 (2) | 8 / 50 (16) | -14 [-25; -3] | 0.13 [0.02; 0.96]
Nausea/diarrhea | 1 | 3 / 50 (6) | 7 / 50 (14) | -8 [-20; 4] | 0.43 [0.12; 1.56]
Weight loss >10% | 1 | 1 / 50 (2) | 7 / 50 (14) | -12 [-22; -2] | 0.14 [0.02; 1.12]
Versus combined interferon-α-2b and lamivudine^63^,^64^–^67^
Subjects not completing treatment/study | 5 | 21 / 267 (7.9) | 18 / 257 (7) | 0 [-6; 6] | 0.98 [0.37; 2.64] | 24–208 weeks
AE leading to discontinuation of study drug | 4 | 3 / 192 (1.6) | 8 / 181 (4.4) | -2 [-8; 3] | 0.42 [0.08; 2.28] | 52–208 weeks
Influenza-like symptoms^66^ | 1 | 12 / 75 (16) | 47 / 76 (61.8) | -46 [-60; -32] | 0.26 [0.15; 0.45] | 100 weeks
Pyrexia^67^ | 1 | 6 / 84 (7.1) | 46 / 76 (48.7) | -53 [-66; -41] | 0.12 [0.05; 0.26] | 24–52 weeks
Fatigue ^67^ | 1 | 35 / 84 (41.7) | 66 / 76 (86.8) | -45 [-58; -32] | 0.48 [0.37; 0.63]
Fatigue^66^ | 1 | 8 / 75 (10.7) | 8 / 76 (10.5) | 0 [-10; 10] | 1.01 [0.40; 2.56] | 100 weeks
Myalgia^67^ | 1 | 11 / 84 (13.1) | 36 / 76 (47.4) | -34 [-48; -21] | 0.28 [0.15; 0.50] | 24–52 weeks
Arthralgia^67^ | 1 | 4 / 84 (4.8) | 9 / 76 (11.8) | -7 [-16; 1] | 0.40 [0.13; 1.25]
Headache^67^ | 1 | 27 / 84 (32.1) | 71 / 76 (93.4) | -61 [-73; -50] | 0.34 [0.27; 0.47]
Headache^66^ | 1 | 7 / 75 (9.3) | 8 / 76 (10.5) | -1 [-11; 8] | 0.89 [0.34; 2.32] | 100 weeks
Nausea^67^ | 1 | 19 / 84 (22.6) | 33 / 76 (43.4) | -21 [-35; -7] | 0.52 [0.33; 0.83] | 24–52 weeks
Nausea^66^ | 1 | 5 / 75 (6.7) | 7 / 76 (9.2) | -3 [-11; 6] | 0.72 [0.24; 2.18] | 100 weeks
Alopecia^67^ | 1 | 8 / 84 (9.5) | 30 / 76 (39.5) | -30 [-43; -17] | 0.24 [0.12; 0.49] | 24–52 weeks
Feeding problems / anorexia^67^ | 1 | 4 / 84 (4.8) | 30 / 76 (39.5) | -35 [-47; -23] | 0.12 [0.04; 0.33] | 24–52 weeks
Viral respiratory infections^67^ | 1 | 25 / 84 (29.8) | 32 / 76 (42.1) | -12 [-27; 2] | 0.71 [0.46; 1.08]
Versus combined interferon-α-2b and lamivudine, subjects refractory interferon therapy ^47^
Subjects not completing treatment / study | 1 | 9 / 119 (7.6) | 10 / 63 (15.9) | -8 [-19; 2] | 0.48 [0.20; 1.11] | 68 weeks
AE leading; discontinuation of study drug | 1 | 1 / 119 (<1) | 1 / 63 (1.6) | -1 [-4; 3] | 0.53 [0.03; 8.32] | 68 weeks
| | | | | | 68 weeks
Pyrexia | 1 | 6 / 119 (5) | 38 / 63 (60.3) | -55 [-68; -43] | 0.08 [0.04; 0.19] | 68 weeks
| | | | | | 68 weeks
Fatigue | 1 | 18 / 119 (15.1) | 38 / 63 (60.3) | -45 [-59; -32] | 0.25 [0.16; 0.40] | 68 weeks
| | | | | | 68 weeks
Myalgia | 1 | 13 / 119 (10.9) | 18 / 63 (28.6) | -18 [-30; -5] | 0.38 [0.20; 0.73] | 68 weeks
| | | | | | 68 weeks
Headache | 1 | 10 / 119 (8.4) | 30 / 63 (47.6) | -39 [-53; -26] | 0.18 [0.09; 0.34]
Nausea | 1 | 12 / 119 (10.1) | 23 / 63 (36.5) | -26 [-39; -13] | 0.28 [0.15; 0.52]
Alopecia | 1 | 1 / 119 (<1) | 19 / 63 (30.2) | -29 [-41; -18] | 0.03 [0.00; 0.20]
Feeding problems / anorexia | 1 | 1 / 119 (<1) | 12 / 63 (19) | -18 [-28; -8] | 0.04 [0.01; 0.33]
Viral respiratory infections or | 1 | 2 / 119 (1.7) | 14 / 63 (22.2) | -21 [-31; -10] | 0.08 [0.02; 0.32]
Depression | 1 | 3 /119 (2.5) | 11 / 63 (17.5) | -15 [-25; -5] | 0.14 [0.04; 0.50]
Shi, 2006 ^62^
Any adverse event | 1 | 0 / 98 | NR | | | 72 weeks
Serious adverse event | 1 | 0 / 98 | 6 / 64 (9.4) Pyrexia, fatigue, myalgia, headache | -9 [-17; -2] | 0.05 [0.00; 0.88]
(E) Telbivudine ([underlined: L-nucleoside analog])
Versus adefovir (see above)
Versus lamivudine, attributed to study drug (SEBIVO INSERT - 007 GLOBE)^71^
Subjects not completing treatment/study | 1 | 18 / 680 (2.6) | 32 / 687 (4.7) | -2 [-4; 0] | 0.57[0.32; 1.00] | 52 weeks
Any adverse event | | NR | NR | | | 52 weeks
| | | | | | 52 weeks
Serious adverse event | 1 | 18 / 680 (2.6) | 33 / 687 (4.8) | -2 [-4; 0] | 0.55 [0.31; 0.97] | 52 weeks
| | | | | | 52 weeks
AE leading to discontinuation of study drug | 1 | 2 / 680 (<1) | 5 / 687 (<1) | 0 [-1; 0] | 0.40 [0.08; 2.08] | 52 weeks
| | | | | | 52 weeks
AE leading to discontinuation, possibly related to study drug | 1 | 1 / 680 myopathy | 1 / 687 urticaria | 0 [0; 0] | 1.01 [0.06; 16.12 | 52 weeks
| | | | | | 52 weeks
Fatigue | 1 | 29 / 680 (4.3) | 18 / 687 (2.6) | 2 [0; 4] | 1.63 [0.91; 2.90] | 52 weeks
| | | | | | 52 weeks
Nausea | 1 | 19 / 680 (2.8) | 15 / 687 (2.2) | 1 [-1; 2] | 1.28 [0.66; 2.50] | 52 weeks
Diarrhea | 1 | 10 / 680 (1.5) | 4 / 687 (<1) | 1 [0; 2] | 2.53 [0.80; 8.01]
Abdominal pain | 1 | 7 / 680 (1.0) | 1 / 687 (<1) | 1 [0; 2] | 7.07 [0.87; 57.33]
Headache | 1 | 22 / 680 (3.2) | 27 / 687 (3.9) | -1 [-3; 1] | 0.82 [0.47; 1.43]
Dizziness | 1 | 10 / 680 (1.5) | 5 / 687 (<1) | 1 [0; 2] | 2.02 [0.69; 5.88]
Rash | 1 | 9 / 680 (1.3) | 7 / 687 (1.0) | 0 [-1; 1] | 1.30 [0.49; 3.47]
Nasopharyngitis | 1 | 7 / 680 (1.0) | 4 / 687 (<1) | 0 [-1; 1] | 1.77 [0.52; 6.01]
Cough | 1 | 7 / 680 (1.0) | 3 / 687 (<1) | 1 [0; 1] | 2.36 [0.61; 9.08]
Versus lamivudine (SEBIVO INSERT - 007 GLOBE)^71^
Upper respiratory tract infection | 1 | 82 / 680 (12.1) | 82 / 687 (11.9) | 0 [-3; 4] | 1.01 [0.76; 1.35] | 52 weeks
Nasopharyngitis | 1 | 68 / 680 (10) | 69 / 687 (10) | 0 [-3; 3] | 1.00 [0.72; 1.37] | 52 weeks
| | | | | | 52 weeks
Fatigue | 1 | 68 / 680 (10) | 62 / 687 (9.0) | 1 [-2; 4] | 1.11 [0.80; 1.54] | 52 weeks
Headache | 1 | 68 / 680 (10) | 82 / 687 (11.9) | -2 [-5; 1] | 0.84 [0.62; 1.13]
Dizziness | 1 | 27 / 680 (4.0) | 34 / 687 (4.9) | -1 [-3; 1] | 0.80 [0.49; 1.31]
Myalgia | 1 | 20 / 680 (2.9) | 14 / 687 (2.0) | 1 [-1; 3] | 1.44 [0.74; 2.83]
(F) Entecavir monotherapy ([underlined: Acyclic guanosine derivative])
0.5 mg dose versus lamivudine ^73,^ ^74^
Subjects not completing study/treatment | 2 | 37 / 688* (5.4) | 58 / 675 (8.6) | -3 [-8; 2] | 0.64 [0.33; 1.26] | E=56–75 weeks L=56–65 weeks
Any adverse event | 2 | 552 / 679 (80.3) | 545 / 668 (81.1) | 0 [-6; 6] | 1.00 [0.92; 1.08] | E=56–75 weeks L=56–65 weeks
Serious adverse event | 2 | 48 / 679 (7.1) | 54 / 668 (8.1) | -1 [-4; 2] | 0.88 [0.60; 1.27]
AE leading to discontinuation of study drug | 2 | 7 / 679 (1.0) | 18 / 668 (2.7) | -2 [-3; 0] | 0.33 [0.06; 1.86]
Lai 2005 0.5 mg dose versus lamivudine ^77^
Any adverse event | 1 | 30 / 46 (65.2) | 30 / 41 (73.1) | -8 [-27; 11] | 0.89 [0.67; 1.18] | 24 weeks
AE leading to discontinuation of study drug | 1 | 0 / 46 | 1 / 41 (2.4) | -2 [-9; 4] | 0.30 [0.01; 7.12] | 24 weeks
| | | | | | 24 weeks
Headache | 1 | 14 / 46 (30.4) | 8 / 41 (19.5) | 11 [-7; 29] | 1.56 [0.73; 3.33] | 24 weeks
| | | | | | 24 weeks
Abdominal pain | 1 | 12 / 46 (26.1) | 7 / 41 (17.1) | 9 [-8; 26] | 1.53 [0.67; 3.51] | 24 weeks
| | | | | | 24 weeks
Rhinitis | 1 | 5 / 46 (10.9) | 8 / 41 (19.5) | -9 [-24; 6] | 0.56 [0.20; 1.57] | 24 weeks
| | | | | | 24 weeks
Fatigue | 1 | 8 / 46 (17.4) | 7 / 41 (17.1) | 0 [-16; 16] | 1.02 [0.40; 2.56] | 24 weeks
Pyrexia | 1 | 2 / 46 (4.3) | 6 / 41 (14.6) | -10 [-23; 2] | 0.30 [0.06; 1.39]
Diarrhea | 1 | 5 / 46 (10.9) | 4 / 41 (9.8) | 1 [-12; 14] | 1.11 [0.32; 3.87]
Nausea | 1 | 5 / 46 (10.9) | 3 / 41 (7.3) | 4 [-8; 16] | 1.49 [0.38; 5.83]
Dizziness | 1 | 5 / 46 (10.9) | 2 / 41 (4.9) | 6 [-5; 17] | 2.23 [0.46; 10.87]
Cough | 1 | 2 / 46 (4.3) | 2 / 41 (4.9) | -1 [-9; 8] | 0.89 [0.13; 6.04]
Myalgia | 1 | 0 / 46 | 4 / 41 (9.8) | -10 [-20; 0] | 0.10 [0.01; 1.79]
1 mg dose versus lamivudine in lamivudine-refractory subjects patient information sheet (Bristol Myers Squibb)
Any Grade II to IV adverse event | 2 | 40 / 183 (21.9) | 44 / 190 (23.2) | -1 [-10; 7] | 0.94 [0.87; 1.14] | Through 2 years
Fatigue | 2 | 5 / 183 (2.7) | 6 / 190 (3.2) | 0 [-4; 3] | 0.87 [0.27; 2.79]
Headache | 2 | 7 / 183 (3.8) | 2 / 190 (1.1) | 3 [0; 6] | 3.63 [0.76; 17.26]
Versus lamivudine in lamivudine-refractory subjects Chang, 2005 #52}^75^
Subjects not completing study/treatment (24 weeks) | 1 | 7 / 136 (5.1) All doses** | 2 / 45 (4.4) | 1 [-6; 8] | 1.16 [0.25; 5.37] | 24 weeks
Subjects not completing study / treatment (48 weeks) | 2 | 39 / 283* (13.9) | 38 / 191* (19.9) | -12 [-30; 6] | 0.54 [0.36; 0.81] | 48 weeks
Any adverse event | 2 | 225 / 277 (81.2) | 155 / 190 (81.6) | 0 [-12; 11] | 0.99 [0.87; 1.14] | 48 weeks
| | | | | | 48 weeks
Serious adverse event | 2 | 22 / 277 (7.9) | 14 / 190 (7.4) | 1 [-4; 6] | 1.18 [0.62; 2.27] | 48 weeks
| | | | | | 48 weeks
Severe (grade III or IV) AE | 1 | 32 / 136 (23.5) | 9 / 45 (20) | 4 [-10; 17] | 1.18 [0.61; 2.27] | 48 weeks
| | | | | | 48 weeks
AE leading to discontinuation of study drug | 2 | 11 / 277 (4.0) | 14 / 190 (7.4) | -5 [-9; 1] | 0.43 [0.12; 1.54] | 48 weeks
| | | | | | 48 weeks
Headache | 1 | 35 / 136 (25.7) | 10 / 45 (22.2) | 4 [-11; 18] | 1.16 [0.63; 2.15] | 48 weeks
| | | | | | 48 weeks
Fatigue | 1 | 23 / 136 (16.9) | 6 / 45 (13.3) | 4 [-8; 15] | 1.27 [0.55; 2.92] | 48 weeks
Pyrexia | 1 | 15 / 136 (11) | 3 / 45 (6.7) | 4 [-5; 13] | 1.65 [0.50; 5.45]
Upper respiratory tract infection | 1 | 10 / 136 (7.4) | 6 / 45 (13.3) | -6 [-17; 5] | 0.55 [0.21; 1.43]
Diarrhea | 1 | 14 / 136 (10.3) | 3 / 45 (6.7) | 4 [-5; 13] | 1.54 [0.46; 5.13]
Upper abdominal pain | 1 | 8 / 136 (5.9) | 5 / 45 (11.1) | -5 [-15; 5] | 0.53 [0.18; 1.54]
Back pain | 1 | 13 / 136 (9.6) | 3 / 45 (6.7) | 3 [-6; 12] | 1.43 [0.43; 4.80]
Arthralgia | 1 | 12 / 136 (8.8) | 2 / 45 (4.4) | 4 [-3; 12] | 1.99 [0.46; 8.54]
Nasopharyngitis | 1 | 11 / 136 (8.1) | 5 / 45 (11.1) | -3 [-13; 7] | 0.73 [0.27; 1.98]
* Includes subjects not receiving any study medication
** 0.1, 0.5, and 1 mg arms
(G) Combination pegylated interferon-α-2a and lamivudine therapy ([underlined: interferon])
Versus lamivudine (see above) ^56,^ ^57^
Versus pegylated interferon-α-2a monotherapy ^56,^ ^57^
Subjects not completing treatment / study | 2 | 49 / 457* (10.7) | 45 / 453* (9.9) | 1 [-4; 5] | 1.08 [0.71; 1.66] | 72 weeks
Any adverse event | 2 | 395 / 450 (87.8) | 395 / 448 (88.2) | 0 [-58; 4] | 1.00 [0.95; 1.05] | 72 weeks
Serious adverse event | 2 | 28 / 450 (6.2) | 21 / 448 (4.7) | 2 [-1; 4] | 1.33 [0.77; 2.30] | 72 weeks
AE leading to discontinuation of study drug | 2 | 19 / 450 (4.2) | 21 / 448 (4.7) | -1 [-6; 4] | 0.90 [0.33; 2.48] | 72 weeks
Pyrexia | 2 | 246 / 450 (54.7) | 238 / 448 (53.1) | 1 [-9; 11] | 1.02 [0.85; 1.22] | 72 weeks
Fatigue | 2 | 176 / 450 (39.1) | 182 / 448 (40.6) | -2 [-8; 5] | 0.96 [0.82; 1.13] | 72 weeks
Myalgia | 2 | 126 / 450 (28.0) | 117 / 448 (26.1) | 2 [-4; 8] | 1.07 [0.86; 1.33] | 72 weeks
Headache | 2 | 115 / 450 (25.6) | 118 / 448 (26.3) | -1 [-8; 5] | 0.96 [0.74; 1.26] | 72 weeks
Alopecia | 2 | 98 / 450 (21.8) | 79 / 448 (17.6) | 3 [-8; 14] | 1.14 [0.68; 1.92] | 72 weeks
Decreased appetite | 2 | 60 / 450 (13.3) | 71 / 448 (15.8) | -2 [-7; 2] | 0.84 [0.61; 1.16] | 72 weeks
Dizziness | 2 | 44 / 450 (9.8) | 40 / 448 (8.9) | 1 [-4; 5] | 1.09 [0.70; 1.70] | 72 weeks
Diarrhea | 2 | 36 / 450 (8.0) | 45 / 448 (10.0) | -2 [-8; 3] | 0.75 [0.36; 1.55] | 72 weeks
Pruritus | 2 | 37 / 450 (8.2) | 35 / 448 (7.8) | 1 [-3; 4] | 1.05 [0.68; 1.64] | 72 weeks
Nausea | 2 | 40 / 450 (8.9) | 38 / 448 (8.5) | 0 [-3; 4] | 1.05 [0.69; 1.60] | 72 weeks
Arthralgia | 2 | 51 / 450 (11.3) | 51 / 448 (11.4) | 0 [-4; 4] | 0.99 [0.69; 1.43] | 72 weeks
Rigors | 2 | 32 / 450 (7.1) | 29 / 448 (6.5) | 0 [-6; 6] | 0.92 [0.33; 2.56] | 72 weeks
Injection-site reaction | 2 | 36 / 450 (8.0) | 34 / 448 (7.6) | 1 [-8; 10] | 1.12 [0.35; 3.64] | 72 weeks
Gingival bleeding | 1 | 15 / 271 (5.5) | 15 / 271 (5.5) | 0 [-4; 4] | 1.00 [0.50; 2.00]
(H) Combination pegylated interferon-α-2b and lamivudine therapy ([underlined: interferon])
Versus pegylated interferon-α-2b monotherapy ^78^
Subjects not completing treatment/study | 1 | 38 / 152* (25) | 37 / 155* (23.9) | 1 [-8; 11] | 1.05 [0.71; 1.55] | 78 weeks
Serious adverse event | 1 | 32 total, 17 probably related to therapy (including hepatitis flare (4), depression (3), severe neutropenia (3), and one case each of psychosis, seizures, pancreatitis, anxiety, dizziness, diarrhea, and syncope. All serious AE were reversible after treatment was stopped. | | | | 78 weeks
| | | | | | 78 weeks
AE leading to discontinuation of study drug | 1 | 12 / 152 (7.9) | 11 / 155 (7.1) | 1 [-5; 7] | 1.11 [0.51; 2.44] | 78 weeks
| | | | | | 78 weeks
Flu-like syndrome | 1 | 96 / 130 (73.8) | 84 / 136 (61.8) | 12 [1; 23] | 1.20 [1.01; 1.41] | 78 weeks
| | | | | | 78 weeks
Headache | 1 | 59 / 130 (45.4) | 55 / 136 (40.4) | 5 [-7; 17] | 1.12 [0.85; 1.48] | 78 weeks
| | | | | | 78 weeks
Fatigue | 1 | 54 / 130 (41.5) | 59 / 136 (43.4) | -2 [-14; 10] | 0.96 [0.72; 1.27] | 78 weeks
| | | | | | 78 weeks
Myalgia | 1 | 42 / 130 (32.3) | 41 / 136 (30.1) | 2 [-9; 13] | 1.07 [0.75; 1.53] | 78 weeks
| | | | | | 78 weeks
Injection-site reaction | 1 | 38 / 130 (29.2) | 36 / 136 (26.5) | 3 [-8; 14] | 1.10 [0.75; 1.63] | 78 weeks
| | | | | | 78 weeks
Alopecia | 1 | 35 / 130 (26.9) | 26 / 136 (19.1) | 8 [-2; 18] | 1.41 [0.90; 2.20] | 78 weeks
Depression | 1 | 28 / 130 (21.5) | 29 / 136 (21.3) | 0 [-10; 10] | 1.01 [0.64; 1.60]
Abdominal pain | 1 | 25 / 130 (19.2) | 26 / 136 (19.1) | 0 [-9; 10] | 1.01 [0.61; 1.65]
Weight loss > 10% | 1 | 25 / 130 (19.2) | 28 / 136 (20.6) | -1 [-11; 8] | 0.93 [0.58; 1.51]
Decreased appetite | 1 | 21 / 130 (16.2) | 22 / 136 (16.2) | 0 [-9; 9] | 1.00 [0.58; 1.73]
Insomnia | 1 | 20 / 130 (15.4) | 11 / 136 (8.1) | 7 [0; 15] | 1.90 [0.95; 3.81]
Arthralgia | 1 | 20 / 130 (15.4) | 22 / 136 (16.2) | -1 [-10; 8] | 0.95 [0.55; 1.66]
Pruritus | 1 | 18 / 130 (13.8) | 14 / 136 (10.3) | 4 [-4; 11] | 1.35 [0.70; 2.59]
Diarrhea | 1 | 14 / 130 (10.8) | 15 / 136 (11) | 0 [-8; 7] | 0.98 [0.49; 1.94]
Nausea | 1 | 14 / 130 (10.8) | 25 / 136 (18.4) | -8 [-16; 1] | 0.59 [0.32; 1.08]
(I) Pegylated interferon-α-2b versus Interferon-α-2b ([underlined: interferon])
Zhao 2007 ^81^
Subjects not completing treatment/study | 1 | 7 / 115 (6.1) | 20 / 115 (17.4) | -11 [-19; -3] | 0.35 [0.15; 0.80] | 72 weeks
AE leading to discontinuation of study drug | 1 | 0 / 115 | 4 / 115 (3.5) | -3 [-7; 0] | 0.11 [0.01; 2.04]
Any adverse event | 75% of patients in each treatment group experienced various clinical forms of drug-related adverse effects, mainly flulike symptoms and fever. Two patients with an increased ALT level experienced nausea and vomiting and discontinued treatment. Only 1 patient who received pegylated IFN-a-2b experienced nausea and vomiting but discontinuation of treatment was not required.
(J) Interferon-α-2b and Lamivudine ([underlined: Interferon])
Versus placebo, subjects refractory interferon therapy ^47^
Subjects not completing treatment/study | 1 | 10 / 63 (15.9) | 10 / 56 (17.9) | -2 [-15; 12] | 0.89 [0.40; 1.98] | 68 weeks
Any adverse event | 1 | NR | NR | - | - | 68 weeks
| | | | | | 68 weeks
Serious adverse event | 1 | NR | NR | - | - | 68 weeks
| | | | | | 68 weeks
AE leading to discontinuation of study drug | 1 | 1 / 63 (1.6) | 4 / 56 (7.1) | -6 [-13; 2] | 0.22 [0.03; 1.93] | 68 weeks
| | | | | | 68 weeks
Pyrexia | 1 | 38 / 63 (60.3) | 0 / 56 | 60 [48; 73] | 68.58 [4.31; >1000] | 68 weeks
| | | | | | 68 weeks
Fatigue | 1 | 38 / 63 (60.3) | 10 / 56 (17.9) | 42 [27; 58] | 3.38 [1.86; 6.13] | 68 weeks
| | | | | | 68 weeks
Myalgia | 1 | 18 / 63 (28.6) | 3 / 56(5.4) | 23 [11; 36] | 5.33 [1.66; 17.15]
Headache | 1 | 30 / 63 (47.6) | 7 / 56 (12.5) | 35 [20; 50] | 3.81 [1.82; 7.98]
Nausea | 1 | 23 / 63 (36.5) | 6 / 56 (10.7) | 26 [11; 40] | 3.41 [1.50; 7.76]
Alopecia | 1 | 19 / 63 (30.2) | 1 / 56 (1.8) | 28 [17; 40] | 16.89 [2.34; 122.13]
Feeding problems | 1 | 12 / 63 (19.0) | 1 / 56 (1.8) | 17 [7; 28] | 10.67 [1.43; 79.45]
Viral respiratory infections | 1 | 14 / 63 (22.2) | 0 / 56 | 22 [12; 33] | 25.83 [1.58; 423.25]
Depression | 1 | 11 / 63 (17.5) | 1 / 56 (1.8) | 16 [6; 26] | 9.78 [1.30; 73.36]
Versus IFN monotherapy ^67^
Subjects not completing treatment / study | 1 | 6 / 76 (7.9) | 6 / 70 (8.6) | -1 [-10; 8] | 0.92 [0.31; 2.72] | 24–52 weeks
Pyrexia | 1 | 46 / 76 (60.5) | 43 / 70 (61.4) | -1 [-17; 15] | 0.99 [0.76; 1.28] | 24–52 weeks
| | | | | | 24–52 weeks
Fatigue | 1 | 66 / 76 (86.8) | 70 / 70 (100) | -13 [-21; -5] | 0.87 [0.79; 0.95] | 24–52 weeks
| | | | | | 24–52 weeks
Myalgia | 1 | 36 / 76 (47.4) | 40 / 70 (57.1) | -10 [-26; 6] | 0.83 [0.61; 1.13] | 24–52 weeks
| | | | | | 24–52 weeks
Arthralgia | 1 | 9 / 76 (11.8) | 23 / 70 (32.9) | -21 [-34; -8] | 0.36 [0.18; 0.72] | 24–52 weeks
Headache | 1 | 71 / 76 (93.4) | 47 / 70 (67.1) | 26 [14; 39] | 1.39 [1.17; 1.66]
Nausea | 1 | 33 / 76 (43.4) | 34 / 70 (48.6) | -5 [-21; 11] | 0.89 [0.63; 1.27]
Alopecia | 1 | 30 / 76 (39.5) | 21 / 70 (30) | 9 [-6; 25] | 1.32 [0.84; 1.27]
Feeding problems / anorexia | 1 | 30 / 76 (39.5) | 33 / 70 (47.1) | -8 [-24; 8] | 0.84 [0.58; 1.22]
Viral respiratory infections | 1 | 32 / 76 (42.1) | 37 / 70 (52.9) | -11 [-27; 5] | 0.80 [0.56; 1.12]
Versus IFN monotherapy^79^
Subjects not completing treatment/study | 1 | 0 / 33 | 1 subject | - | - | 52 weeks
Serious adverse event | 1 | 0 / 33 | 0 / 16 | 0 | -
Mouth dryness | 1 | 25 / 33 (75.6) | 3 / 16 (33.3) | 57 [33; 81] | 4.04 [1.43; 11.41]
Malaise | 73% all patients combined
Alopecia | 64% all patients combined
Myalgia | 61% all patients combined
Pyrexia | 50% all patients combined
Weight loss | 50% all patients combined
Anorexia | 47% all patients combined
12 versus 16 week, subjects refractory interferon therapy^80^
| 1 | Dose reduction was required in one subject (20 total) for malaise and fatigue, and symptoms responded to dose reduction. For another subject, treatment was stopped after 15 weeks of treatment. | | | | 32 weeks
(K) Interferon-α-2b monotherapy ([underlined: Interferon])
Chung, 2003^82^ Prolonged individualized versus 6 months treatment (N=65, all subjects combined). Flu-like symptoms 51/65 (90.8); anorexia/nausea 14/65 (21.5); weight loss >10% 7/65 (10.8); oral ulcer 1/65 (1.5); emotional liability 2/65 (3.1)
Janssen, 1999^83^ Prolonged (32 weeks) versus standard (16 weeks) duration
Hair loss | Significant difference (P < 0.05) between the two groups
Dose reduction due to AE | 11.5% (7/61) in the prolonged group. Due to depression, fatigue, hair loss, and headache. Not reported in standard group.
AE leading to discontinuation of study drug | 4.9% (3/61) in the prolonged group. Not reported in standard group.
Phase A - all subjects prior to randomization (n=162) | Dose modification due to AE: 16/162 (10%). 11 stopped treatment prior to randomization due to flu-like symptoms (3), psychosis/depression (3), dizziness (2), fatigue (1) thrombocytopenia (1), and exacerbation of HBV (1). AE in ≥20% of subjects included fatigue, asthenia, anorexia, arthralgia, and depression/irritability.
Lampertico, 1997^84^ IFN (n=21) versus no treatment (n=21). Study duration was 104 weeks. 5/21 (23.8%) IFN subjects withdrew from study due to persistent headache (1) persistent myalgias, arthralgias or headache (3), and depression (1). Dose in reduction in two subjects due to mild depression (1) and myalgias (1).
Di Bisceglie, 1993^86^ IFN (n=25) versus no treatment (n=22). Study duration was 6 months. IFN AE included flu-like syndrome, headache, fatigue, and muscle aches. Treatment stopped in three subjects due to severe fatigue (1), thrombocytopenia (1), and exacerbation of osteoarthritis. Dose in reduction in 16 subjects due to (could be multiple reasons) fatigue (12), nausea (3), marrow suppression (2), arthralgia (2), infections (2), jaundice (1), and depression (1).
Versus no treatment
Lopez-Alcorocho, 1997^85^ 6 months (n=19) versus 12 months (n=19). “Treatment was well tolerated by all subjects who finished the study, and no dose modification was needed.”
Waked, 1990^89^. IFN (n=20) versus no treatment (n=20). Study duration was 68 weeks. 4 (3 deaths) IFN and 5 (2 deaths) did not complete study. All subjects developed flu-like symptoms (pyrexia, myalgia, chills, and occasionally arthralgias). Other AE were mild and transient and did not lead to study withdrawal.
Muller, 1990^87^ IFN (n=30) versus no treatment (n=28). Study duration was 10 months. “Treatment generally well tolerated.” All patients treated with IFN showed mild flu-like symptoms which disappeared in the majority of patients. One subject with a pre-existing depressive state converted to overt depression. This subject was taken off treatment.
Hadziyannis, 1990^88^ IFN (n=25) versus no treatment (n=25). Study duration was 52 weeks. IFN therapy well tolerated, no serious AE observed. Fever, fatigue, and headache were commonly associated with treatment.

Table E8 Number of subjects with laboratory abnormalities from RCTS

(A) Adefovir monotherapy ([underlined: L-nucleotide analog)]
Laboratory Abnormality | Number of Studies | Treatment n / N (%) | Control n / N (%) | Absolute Risk Difference [95% CI] | Relative Risk Ratio [95% CI] | Trial(s) Duration
Versus placebo [From Gilead Sciences package insert]
ALT: >5 × ULN | 2 | 59 / 294 (20.1) | 93 / 228 (40.8) | -21 [-29; -13] | 0.49 [0.37; 0.65] | 48 weeks
Hematuria: ≥ 3+ | 2 | 32 / 294 (10.9) | 23 / 228 (10.1) | 1 [-4; 6] | 1.08 [0.65; 1.79] | 48 weeks
| | | | | | 48 weeks
AST: >5 × ULN | 2 | 24 / 294 (8.2) | 52 / 228 (22.8) | -15 [-21; -8] | 0.36 [0.23; 0.56] | 48 weeks
Creatine kinase: > 4 × ULN | 2 | 21 / 294 (7.1) | 16 / 228 (7.0) | 0 [-4; 5] | 1.02 [0.54; 1.91]
Amylase: <2 × ULN | 2 | 12 / 294 (4.1) | 9 / 228 (3.9) | 0 [-3; 4] | 1.03 [0.44; 2.41]
Glycosuria: ≥3+ | 2 | 3 / 294 (1.0) | 7 / 228 (3.1) | -2 [-5; 0] | 0.33 [0.09; 1.27]
Versus lamivudine, subjects with lamivudine resistance: Grade 3 and 4 laboratory toxicity ^43^
ALT: >5 × ULN | 1 | 7 / 19 (36.8) | 3 / 19 (15.8) | 21 [-6; 48] | 2.33 [0.71; 7.70] | 48 weeks
AST: >5 × ULN | 1 | 1 / 19 (5.3) | 3 / 19 (15.8) | -11 [-30; 9] | 0.33 [0.04; 2.93] | 48 weeks
| | | | | | 48 weeks
Amylase | 1 | 0 / 19 | 3 / 19 (15.8) | -16 [-34; 2] | 0.14 [0.01; 2.59]
Serum glucose | 1 | 2 / 19 (10.5) | 3 / 19 (15.8) | -5 [-27; 16] | 0.67 [0.13; 3.55]
Glycosuria | 1 | 2 / 19 (10.5) | 4 / 19 (21.1) | -11 [-33; 12] | 0.50 [0.10; 2.41]
Versus telbivudine ^44^
Neutropenia | 1 | Two cases of Grade 3 and 4 neutropenia were observed in one telbivudine subject and one adefovir; telbivudine subject. Both cases resolved without dose reduction/treatment interruption. | | | | 52 weeks
(B) Adefovir versus combination therapy
Laboratory Abnormality | Number of Studies | Treatment n / N (%) | Control n / N (%) | Absolute Risk Difference [95% CI] | Relative Risk Ratio [95% CI] | Trial(s) Duration
Versus combined lamivudine and adefovir, subjects refractory; lamivudine: Grade 3 and 4 laboratory toxicity ^43^
ALT: >5 × ULN | 1 | 7 / 19 (36.8) | 2 / 20 (10) | 27 [1; 52] | 3.68 [0.87; 15.56] | 48 weeks
AST: >5 × ULN | 1 | 1 / 19 (5.3) | 0 / 20 | 5 [-8; 19] | 3.15 [0.14; 72.88] | 48 weeks
| | | | | | 48 weeks
Amylase | 1 | 0 / 19 | 2 / 20 (10) | -10 [-25; 5] | 0.21 [0.01; 4.11]
Serum glucose | 1 | 2 / 19 (10.5) | 1 / 20 (5) | 6 [-11; 22] | 2.11 [0.21; 21.36]
Glycosuria | 1 | 2 / 19 (10.5) | 1 / 20 (5) | 6 [-11; 22] | 2.11 [0.21; 21.36]
(C) Lamivudine monotherapy ([underlined: L-nucleoside analog)]
Adverse Event | Number of Studies | Treatment n / N (%) | Control n / N (%) | Absolute Risk Difference [95% CI] | Relative Risk Ratio [95% CI] | Trial(s) Duration
Versus placebo, 100 and 25 mg doses combined ^50^
Abnormal liver-function tests | 1 | 9 / 285 (3.2) | 6 / 73 (8.3) | -5 [-12; 2] | 0.38 [0.14; 1.04] | 52 weeks
Abnormal liver-function tests deemed; be of major clinical concern | 1 | 5 / 285 (1.8) (25 mg=1; 100 mg=4) | 5 / 73 (6.9) | -5 [-11; 1] | 0.26 [0.08; 0.86]
Abnormal ALT or ASP | 1 | 3 / 285 (1.1) | 3 / 73 (4.1) | -3 [-8; 2] | 0.26 [0.05; 1.24]
Versus placebo ^48^
ALT: ≥2 × baseline level | 1 | 18 / 70 (25.7) | 19 / 71 (26.8) | -1 [-16; 13] | 0.96 [0.55; 1.67] | 52 weeks (during therapy)
ALT: ≥3 × baseline level | 1 | 7 / 70 (10) | 9 / 71 (12.7) | -3 [-13; 8] | 0.79 [0.31; 2.00] | 52 weeks (during therapy)
ALT: ≥2 × baseline level and >500 U/liter | 1 | 1 / 70 (1.4) | 7 / 71 (9.9) | -8 [-16; -1] | 0.14 [0.02; 1.15]
ALT: Grade III or IV abnormality | 1 | 7 / 70 (10) | 9 / 71 (12.7) | -3 [-13; 8] | 0.79 [0.31; 2.00]
Albumin: Grade III or IV abnormality | 1 | 0 / 70 (0) | 2 / 71 (2.8) | -3 [-7; 2] | 0.20 [0.01; 4.15] | 68 weeks
Amylase: Grade III or IV abnormality | 1 | 0 / 70 (0) | 1 / 71 (1.4) | -1 [-5; 2] | 0.34 [0.01; 8.16] | 68 weeks
| | | | | | 68 weeks
Lipase: Grade III or IV abnormality | 1 | 6 / 70 (8.6) | 5 / 71 (7.0) | 2 [-7; 10] | 1.22 [0.39; 3.81]
Creatine kinase: Grade III or IV abnormality | 1 | 6 / 70 (8.6) | 3 / 71 (4.2) | 4 [-4; 12] | 2.03 [0.53; 7.79]
Platelets: Grade III or IV abnormality | 1 | 0 / 70 (0) | 2 / 71 (2.8) | -3 [-7; 2] | 0.20 [0.01; 4.15]
Versus placebo following treatment ^48^
ALT: Grade III abnormality | 1 | 14 / 65 (21.5) | 4 / 66 (6.1) | 15 [4; 27] | 3.55 [1.23; 10.23] | 16 weeks post-treatment (after 52 weeks therapy)
ALT: Grade IV abnormality | 1 | 2 / 65 (3.1) | 1 / 66 (1.5) | 2 [-4; 7] | 2.03 [0.19; 21.85] | 16 weeks post-treatment (after 52 weeks therapy)
| | | | | | 16 weeks post-treatment (after 52 weeks therapy)
ALT: ≥2 × baseline level | 1 | 19 / 65 (29.2) | 13 / 66 (19.7) | 10 [-5; 24] | 1.48 [0.80; 2.75] | 16 weeks post-treatment (after 52 weeks therapy)
ALT: ≥3 × baseline level | 1 | 16 / 65 (24.6) | 5 / 66 (7.6) | 17 [5; 29] | 3.25 [1.26; 8.35]
ALT: ≥2 × baseline level and >500 U/liter | 1 | 12 / 65 (18.5) | 6 / 66 (9.1)
ALT: ≥2 × baseline levels and bilirubin ≥2 × baseline levels | 1 | 1 subject | 1 subject
Versus placebo^46^
ALT: Grade III or IV abnormality | 1 | 17 / 89 (19.1) | 19 / 47 (40.4) | -21 [-38; -5] | 0.47 [0.27; 0.82] | 78 weeks
Increased ALT | 1 | 11 / 89 (12.4) | 6 / 47 (12.8) | 0 [-12; 11] | 0.97 [0.38; 2.45] | 78 weeks
| | | | | | 78 weeks
Hyperbilirubinemia | 1 | 1 subject | 1 subject | | | 78 weeks
| | | | | | 78 weeks
Increased creatine kinase | 1 | 3 / 89 (3.4) | 3 / 47 (6.4) | -3 [-11; 5] | 0.53 [0.11; 2.52] | 78 weeks
Increased amylase | 1 | 3 / 89 (3.4) | 0 / 47 | 3 [-2; 8] | 3.73 [0.20; 70.79]
Prolonged prothrombin time | 1 | 1 / 89 (1.1) | 3 / 47 (6.4) | -5 [-13; 2] | 0.18 [0.02; 1.65]
Low neutrophil count | 1 | 0 | 1 subject
Thrombocytopenia | 1 | 7 / 89 (7.9) | 3 / 47 (6.4) | 1 [-7; 10] | 1.23 [0.33; 4.55]
Versus placebo, subjects refractory interferon therapy ^47^
Abnormal ALT or ASP | 1 | 13 / 119 (10.9) | 5 / 56 (8.9) | 2 [-7; 11] | 1.22 [0.46; 3.26] | 68 weeks
Abnormal enzymes (amylase/CPK) | 1 | 11 / 119 (9.2) | 2 / 56 (3.6) | 6 [-1; 13] | 2.59 [0.59; 11.29]
Versus placebo, during treatment (0; week 52), subjects refractory interferon therapy ^47^
ALT: ≥2 × baseline level | 1 | 31 / 119 (26.1) | 11 / 56 (19.6) | 6 [-7; 19] | 1.33 [0.72; 2.44] | 52 weeks
ALT: ≥3 × baseline level | 1 | 20 / 119 (16.8) | 7 / 56 (12.5) | 4 [-7; 15] | 1.34 [0.60; 2.99]
ALT: ≥2 × baseline level and >500 U/liter | 1 | 9 / 119 (7.6) | 4 / 56 (7.1) | 0 [-8; 9] | 1.06 [0.34; 3.29]
Versus placebo post-treatment, subjects refractory interferon therapy ^47^
ALT: ≥2 × baseline level | 1 | 17 / 67 (25.4) | 7 / 47 (14.9) | 10 [-4; 25] | 1.70 [0.77; 3.78] | 16 weeks post-treatment
ALT: ≥3 × baseline level | 1 | 13 / 67 (19.4) | 4 / 47 (8.5) | 11 [-1; 23] | 2.28 [0.79; 6.56]
ALT: ≥2 × baseline level and >500 U/liter | 1 | 9 / 67 (13.4) | 2 / 47 (4.3) | 9 [-1; 19] | 3.16 [0.71; 13.95]
Lamivudine maintained during followup period versus placebo, subjects refractory interferon therapy ^47^
ALT: ≥2 × baseline level | 1 | 6 / 44 (13.6) | 7 / 47 (14.9) | -1 [-16; 13] | 0.92 [0.33; 2.51] | 16 weeks post-treatment
ALT: ≥3 × baseline level | 1 | 3 / 44 (6.8) | 4 / 47 (8.5) | -2 [-13; 9] | 0.80 [0.19; 3.38]
ALT: ≥2 × baseline level and >500 U/liter | 1 | 3 / 44 (6.8) | 2 / 47 (4.3) | 3 [-7; 12] | 1.60 [0.28; 9.14]
Versus placebo, subjects with advanced liver disease ^51^
ALT: ≥3 × baseline | 1 | 52 / 436 (11.9) | 54 / 215 (25.1) | -13 [-20; -7] | 0.47 [0.34; 0.67] | 32 months (median)
Versus adefovir (see above)
Versus telbivudine(see below)
Versus entecavir (see below)
Versus pegylated interferon-α-2a ^56,^ ^57^
Dose modification | 2 | 0 / 453 | 207 / 448 (46.2) | -46 [-51; -42] | 0.00 [0.00; 0.03] | 72 weeks
Dose modification due; lab abnormality | 2 | 0 / 453 | 164 / 448 (36.6) | -37 [-41; -32] | 0.01 [0.00; 0.04] | 72 weeks
| | | | | | 72 weeks
ALT elevation | 1 | 0 / 181 | 15 / 177 (8.5) | -8 [-13; -4] | 0.03 [0.00; 0.52]
Neutropenia | 1 | 0 / 181 | 30 / 177 (16.9) | -17 [-23; -11] | 0.02 [0.00; 0.26]
Thrombocytopenia | 1 | 0 / 181 | 34 / 177 (19.2) | -19 [-25; -13] | 0.01 [0.00; 0.23]
(D) Lamivudine versus combination therapy
Adverse Event | Number of Studies | Treatment n / N (%) | Control n / N (%) | Absolute Risk Difference [95% CI] | Relative Risk Ratio [95% CI] | Trial(s) Duration
Versus combined lamivudine and adefovir ^58^
Creatinine increase ≥0.5 mg/dL | 1 | 0 / 48 | 0 / 46 | - | - | 52 weeks
Versus combined pegylated interferon-α-2a and lamivudine ^56,^ ^57^
Dose modification | 2 | 0 / 453 | 213 / 450 (47.3) | -47 [-52; -43] | 0.00 [0.00; 0.03] | 72 weeks
Dose modification due; lab abnormality | 2 | 0 / 453 | 166 / 450 (36.9) | -37 [-41; -32] | 0.01 [0.00; 0.04 | 72 weeks
| | | | | | 72 weeks
ALT elevation | 1 | 0 / 181 | 6 / 179 (3.4) | -3 [-6; -1] | 0.08 [0.00; 1.34]
Neutropenia | 1 | 0 / 181 | 44 / 179 (24.6) | -25 [-31; -18] | 0.01 [0.00; 0.18]
Thrombocytopenia | 1 | 0 / 181 | 22 / 179 (12.3) | -12 [-17; -7] | 0.02 [0.00; 0.36]
Versus combined pegylated Interferon-α-2b and lamivudine see below ^59^
Dose modification due; lab abnormality | 1 | 0 / 50 | 5 / 50 (10) | -10 [-19; -1] | 0.09 [0.01; 1.60] | 76 weeks
Increased ALT level | 1 | 12 / 50 (24) | 8 / 50 (16) | 8 [-8; 24] | 1.50 [0.67; 3.35] | 76 weeks
| | | | | | 76 weeks
Decreased phosphate level | 1 | 1 / 50 (2) | 2 / 50 (4) | -2 [-9; 5] | 0.50 [0.05; 5.34]
Decreased neutrophil count | 1 | 0 | 1 subject
Increased creatine kinase level | 1 | 1 subject | 0
Versus combined interferon-α-2b and lamivudine, Grade 3 and 4 laboratory abnormalities ^66^
ALT | 1 | 9 / 75 (12) | 15 / 76 (19.7) | -8 [-19; 4] | 0.61 [0.28; 1.30] | 100 weeks
Albumin | 1 | 2 / 75 (2.7) | 2 / 76 (2.6) | 0 [-5; 5] | 1.01 [0.15; 7.01] | 100 weeks
| | | | | | 100 weeks
Amylase | 1 | 1 / 75 (1.3) | 2 / 76 (2.6) | -1 [-6; 3] | 0.51 [0.05; 5.47] | 100 weeks
Lipase | 1 | 2 / 75 (2.7) | 4 / 76 (5.3) | -3 [-9; 4] | 0.51 [0.10; 2.68]
Creatine kinase | 1 | 5 /75 (6.7) | 6 / 76 (1.3) | -1 [-10; 7] | 0.84 [0.27; 2.65]
Platelets | 1 | 2 / 75 (2.7) | 2 / 76 (2.6) | 0 [-5; 5] | 1.01 [0.15; 7.01]
Versus combined interferon-α-2b and lamivudine, subjects refractory interferon therapy ^47^
Abnormal ALT/AST | 1 | 13 / 119 (10.9) | 6 / 63 (9.5) | 1 [-8; 11] | 1.15 [0.46; 2.87] | 68 weeks
Abnormal enzymes (amylase/CPK) | 1 | 11 / 119 (9.2) | 5 / 63 (7.9) | 1 [-7; 10] | 1.16 [0.42; 3.20]
Decreased WBCs | 1 | 1 / 119 (<1) | 10 / 63 (15.9) | -15 [-24; -6] | 0.05 [0.01; 0.40]
Versus combined interferon-α-2b and lamivudine, during treatment (0; week 52), subjects refractory interferon therapy ^47^
ALT ≥2 × baseline level | 1 | 31 / 119 (26.1) | 30 / 63 (47.6) | -22 [-36; -7] | 0.55 [0.37; 0.81] | 52 weeks
ALT ≥ 3 × baseline level | 1 | 20 / 119 (16.8) | 13 / 63 (20.6) | -4 [-16; 8] | 0.81 [0.43; 1.53]
ALT ≥2 × baseline level and 500U/I | 1 | 9 / 119 (7.6) | 8 / 63 (12.7) | -5 [-15; 4] | 0.60 [0.24; 1.47]
Versus combined interferon-α-2b and lamivudine, post-treatment, subjects refractory interferon therapy ^47^
ALT ≥2 × baseline level | 1 | 17 / 67 (25.4) | 4 / 53 (7.5) | 18 [5; 30] | 3.36 [1.20; 9.40] | 16 weeks post-treatment
ALT ≥3 × baseline level | 1 | 13 / 67 (19.4) | 2 / 53 (3.8) | 16 [5; 26] | 5.14 [1.21; 21.80]
ALT ≥2 × baseline level and 500 U/I | 1 | 9 / 67 (13.4) | 1 / 53 (1.9) | 12 [3; 20] | 7.12 [0.93; 54.44]
Lamivudine maintained during post-treatment period versus combined interferon-α-2b and lamivudine, subjects refractory interferon therapy Schiff, 2003 #109}
ALT ≥2 × baseline level | 1 | 6 / 44 (13.6) | 4 / 53 (7.5) | 6 [-6; 18] | 1.81 [0.54; 6.00] | 16 weeks post-treatment
ALT ≥3 × baseline level | 1 | 3 / 44 (6.8) | 2 / 53 (3.8) | 3 [-6; 12] | 1.81 [0.32; 10.34]
ALT ≥2 × baseline level and 500 U/I | 1 | 3 / 44 (6.8) | 1 / 53 (1.9) | 5 [-3; 13] | 3.61 [0.39; 33.53]
Versus combined interferon-α-2b and lamivudine ^64^
Dose modification | 1 | none | Possibly 12 subjects, 2 permanent | | | 96 weeks
ALT flare | 1 | 1 / 40 (2.5) | 3 / 40 (7.5) | -5 [-14; 4] | 0.33 [0.04; 3.07] | 96 weeks
| | | | | | 96 weeks
Thrombocytopenia | 1 | 3 / 40 (7.5) | 11 / 40 (27.5) | -20 [-36; -4] | 0.27 [0.08; 0.90]
Leucopenia | 1 | 0 / 40 | 4 / 40 (10) | -10 [-20; 0] | 0.11 [0.01; 2.00]
Versus combined interferon-α-2b and lamivudine, during treatment ^67^
Dose modification | 1 | none | Approx. 20% | | | 24–52 weeks
Hepatic flares (ALT ≥500 IU/l and >2 × baseline | 1 | 10 / 82 (12.2) | 0 / 75 | 12 [5; 20] | 19.23 [1.15; 322.57]
Versus combined interferon-α-2b and lamivudine, post-treatment ^67^
Hepatic flares (ALT ≥500 IU/l and >2 × baseline | 1 | 10 / 78 (12.8) | 5 / 74 (6.8) | 6 [-3; 20] | 1.90 [0.68; 5.29] | 12 weeks post-treatment
Hepatic flares associated with bilirubin >2 ULN | 1 | 2 subjects | 0
(E) Telbivudine ([underlined: L-nucleoside analog)]
Adverse Event | Number of Studies | Treatment n / N (%) | Control n / N (%) | Absolute Risk Difference [95% CI] | Relative Risk Ratio [95% CI] | Trial(s) Duration
Versus adefovir (see above)
Versus lamivudine [SEBIVO Insert- Novartis]
Elevated creatine kinase (CK) leading; study interruption or withdrawal | 1 | 5 / 680 (<1) 3 withdrew | 0 / 687 (0) | 1 [0; 1] | 11.1 [0.62; 200.59] | 52 weeks
Grade 1 CK 1; 3 ULN | 1 | 287 / 680 (42.2) | 203 / 687 (29.5) | 13 [8; 18] | 1.43 [1.24; 1.65] | 52 weeks
| | | | | | 52 weeks
Grade 2 CK >3; 7 ULN | 1 | 123 / 680 (18.1) | 45 / 687 (6.6) | 12 [8; 15] | 2.76 [2.00; 3.82] | 52 weeks
| | | | | | 52 weeks
Grade 3 CK >7; 10 ULN | 1 | 28 / 680 (4.1) | 7 / 687 (1.0) | 3 [1; 5] | 4.04 [1.78; 9.19] | 52 weeks
| | | | | | 52 weeks
Grade 4 CK >10 ULN | 1 | 23 / 680 (3.4) | 14 / 687 (2.0) | 1 [0; 3] | 1.66 [0.86; 3.82] | 52 weeks
| | | | | | 52 weeks
All Grades | 1 | 461 / 680 (67.8) | 269 / 687 (39.2) | 29 [24; 34] | 1.73 [1.56; 1.93] | 52 weeks
| | | | | | 52 weeks
ALT: ≥3 × baseline level | 1 | 25 / 680 (3.7) | 43 / 687 (6.3) | -3 [-5; 0] | 0.59 [0.36; 0.95]
AST: ≥3 × baseline level | 1 | 18 / 680 (2.6) | 32 / 687 (4.7) | -2 [-4; 0] | 0.57 [0.32; 1.00]
Lipase >2.5 × ULN | 1 | 12 / 680 (1.8) | 22 / 687 (3.2) | -1 [-3; 0] | 0.55 [0.72; 1.10]
Amylase >3.0 × ULN | 1 | 1 / 680 (<1) | 2 / 687 (<1) | 0 [-1; 0] | 0.55 [0.72; 1.10]
Total bilirubin >5.0 × ULN | 1 | 0 | 2 subjects | - | -
Neutropenia | 1 | 0 | 1 subject | - | -
Thrombocytopenia | 1 | 0 | 1 subject | - | -
Versus lamivudine, Grade 3–4 laboratory abnormalities from Lai 2007 (Globe Study)^71^
Creatine kinase | 1 | 51 / 680 (7.5) | 21 / 687 (3.1) | 4 [2; 7] | 2.45 [1.49; 4.03] | 52 weeks
Absolute neutrophil count | 1 | 13 / 680 (1.9) | 9 / 687 (1.3) | 1 [-1; 2] | 1.46 [0.63; 3.39]
Platelet count | 1 | 5 / 680 (<1) | 4 / 687 (<1) | 1 [-1; 1] | 1.26 [0.34; 4.68]
(F) Entecavir ([underlined: Acyclic guanosine derivative)]
Laboratory Abnormality | Number of Studies | Treatment n / N (%) | Control n / N (%) | Absolute Risk Difference [95% CI] | Relative Risk Ratio [95% CI] | Trial(s) Duration
Versus lamivudine, nucleoside-naïve subjects, during treatment ^73,^ ^74^
ALT: >2 × baseline level and > 0 × ULN | 2 | 15 / 679 (2.2) | 28 / 668 (4.2) | -2 [-4; 1] | 0.53 [0.29; 0.99] | 52–75 weeks
ALT: >2 × baseline level and >5 × ULN | 2 | 43 / 679 (6.3) | 69 / 668 (10.3) | -3 [-10; 3] | 0.62 [0.43; 0.89]
Versus lamivudine, post-treatment ^73^ ^74^
ALT: >2 × baseline level and >10 × ULN | 2 | 25 / 431 (5.8) | 38 / 392 (9.7) | -4 [-8; -1] | 0.48 [0.16; 1.44] | 24 weeks post-treatment
ALT: >2 × baseline level and >5 × ULN | 2 | 39 / 431 (9) | 93 / 392 (23.7) | -14 [-21; -6] | 0.34 [0.16; 0.69]
Versus lamivudine, nucleoside-naïve subjects. Patient information sheet (trials Bristol Myers Squibb)
Any Grade 3 or 4 Lab abnormality | 2 | 238 / 679 (35.1) | 240 / 668 (35.9) | -1 [-6; 4] | 0.98 [0.84; 1.13] | Through 104 weeks
AST >5 × ULN | 2 | 34 / 679 (5) | 53 / 668 (7.9) | -3 [-6; 0] | 0.63 [0.42; 0.96] | Through 104 weeks
| | | | | | Through 104 weeks
Total bilirubin > 2.5 × ULN | 2 | 14 / 679 (2.1) | 13 / 668 (1.9) | 0 [-1; 2] | 1.06 [0.50; 2.24] | Through 104 weeks
| | | | | | Through 104 weeks
Amylase ≥2.1 × ULN | 2 | 14 / 679 (2.1) | 13 / 668 (1.9) | 0 [-1; 2] | 1.06 [0.50; 2.24] | Through 104 weeks
| | | | | | Through 104 weeks
Lipase ≥2.1 × ULN | 2 | 48 / 679 (7.1) | 40 / 668 (6) | 1 [-2; 4] | 1.18 [0.79; 1.77] | Through 104 weeks
| | | | | | Through 104 weeks
Creatinine ≥3.0 × ULN | 2 | 0 / 679 | 0 / 668
Creatinine increase ≥0.5 mg/dL | 2 | 7 / 679 (1.0) | 7 / 668 (1) | 0 [-1; 1] | 0.98 [0.35; 2.79]
Hyperglycemia, fasting >250 mg/dL | 2 | 14 / 679 (2.1) | 7 / 668 (1) | 1 [0; 2] | 1.97 [0.80; 4.84]
Glycosuria | 2 | 28 / 679 (4.1) | 20 / 668 (3) | 1 [-1; 3] | 1.38 [0.78; 2.42]
Hematuria | 2 | 61 / 679 (9) | 67 / 668 (10) | -1 [-4; 2] | 0.90 [0.64; 1.25]
Platelets <50,000/mm^3^ | 2 | <1% | <1%
1 mg dose versus lamivudine in lamivudine-refractory subjects. Patient information sheet (trials Bristol Myers Squibb)
ALT: >2 × baseline level and >10 × ULN | 2 | 4 / 183 (2.2) | 21 / 190 (11.1) | -9 [-14; -4] | 0.20 [0.07; 0.57] | Through 104 weeks
ALT: >5 × ULN | 2 | 22 / 183 (12) | 46 / 190 (24.2) | -12 [-20; -4] | 0.50 [0.31; 0.79] | Through 104 weeks
| | | | | | Through 104 weeks
Any Grade 3 or 4 Lab abnormality | 2 | 68 / 183 (37.2) | 86 / 190 (45.3) | -8 [-18; 2] | 0.82 [0.64; 1.05] | Through 104 weeks
| | | | | | Through 104 weeks
AST >5 × ULN | 2 | 9 / 183 (4.9) | 32 / 190 (16.8) | -12 [-18; -6] | 0.29 [0.14; 0.59] | Through 104 weeks
| | | | | | Through 104 weeks
Total bilirubin > 2.5 × ULN | 2 | 5 / 183 (2.7) | 4 / 190 (2.1) | 1 [-2; 4] | 1.30 [0.35; 4.76] | Through 104 weeks
| | | | | | Through 104 weeks
Amylase ≥ 2.1 × ULN | 2 | 5 / 183 (2.7) | 6 / 190 (3.2) | 0 [-4; 3] | 0.87 [0.27; 2.79] | Through 104 weeks
| | | | | | Through 104 weeks
Lipase ≥2.1 × ULN | 2 | 13 / 183 (7.1) | 13 / 190 (6.8) | 0 [-5; 5] | 1.04 [0.49; 2.18]
Creatinine ≥3.0 × ULN | 2 | 0 / 183 | 0 / 190 | - | -
Creatinine increase ≥0.5 mg/dL | 2 | 4 / 183 (2.2) | 2 / 190 (1.1) | 1 [-1; 4] | 2.08 [0.39; 11.20]
Hyperglycemia, fasting >250 mg/dL | 2 | 5 / 183 (2.7) | 2 / 190 (1.1) | 2 [-1; 4] | 2.60 [0.51; 13.21]
Glycosuria | 2 | 7 / 183 (3.8) | 11 / 190 (5.8) | -2 [-6; 2] | 0.66 [0.26; 1.67]
Hematuria | 2 | 16 / 183 (8.7) | 11 / 190 (5.8) | 3 [-2; 8] | 1.51 [0.72; 3.17]
Platelets <50,000/mm^3^ | 2 | <1% | <1% | - | -
Lai 2002 ^77^ One entecavir 0.01-mg subject had an increase in ALT level; 1.9 times the baseline level and the bilirubin level increased; 6.2 mg/dL (grade 4 toxicity) leading; drug discontinuation. One lamivudine subject had a grade 4 elevation of ALT level at baseline and was withdrawn from the trial.
(G) Combination pegylated interferon alfa-2a and lamivudine therapy (see under lamivudine)
Adverse Event | Number of Studies | Treatment n / N (%) | Control n / N (%) | Absolute Risk Difference [95% CI] | Relative Risk Ratio [95% CI] | Trial(s) Duration
Versus lamivudine (see above) ^56,^ ^57^
Versus pegylated Interferon alfa-2a monotherapy ^56,^ ^57^
Dose modification | 2 | 213 / 450 (47.3) | 207 / 448 (46.2) | 1 [-5; 8] | 1.02 [0.89; 1.18] | 72 weeks
Dose modification due; lab abnormality | 2 | 166 / 450 (36.9) | 164 / 448 (36.6) | 0 [-6; 7] | 1.01 [0.85; 1.20] | 72 weeks
| | | | | | 72 weeks
ALT elevation^57^ | 1 | 6 / 179 (3.4) | 15 / 177 (8.5) | -5 [-10; 0] | 0.40 [0.16; 1.00]
Neutropenia^57^ | 1 | 44 / 179 (24.6) | 30 / 177 (16.9) | 8 [-1; 16] | 1.45 [0.96; 2.20]
Thrombocytopenia^57^ | 1 | 22 / 179 (12.3) | 34 / 177 (19.2) | -7 [-14; 1] | 0.64 [0.39; 1.05]
(H) Combined pegylated interferon alfa-2b and lamivudine
Adverse Event | Number of Studies | Treatment n / N (%) | Control n / N (%) | Absolute Risk Difference [95% CI] | Relative Risk Ratio [95% CI] | Trial(s) Duration
Versus pegylated interferon-α-2b monotherapy ^78^
Neutropenia (<1.5 × 10^9^/L) | 1 | 34 / 130 (26.2) | 26 / 136 (21.3) | 7 [-3; 17] | 1.37 [0.87; 2.15] | 78 weeks
Thrombocytopenia (<75 × 10^9^/L) | 1 | 14 / 130 (10.8) | 17 / 136 (12.5) | -2 [-9; 6] | 0.86 [0.44; 1.86]
(I) Pegylated interferon alfa-2b versus Interferon alfa-2b ([underlined: Interferon)]
Adverse Event | Number of Studies | Treatment n / N (%) | Control n / N (%) | Absolute Risk Difference [95% CI] | Relative Risk Ratio [95% CI] | Trial(s) Duration
Zhao 2007 ^81^
Subjects with elevated ALT and/or bilirubin discontinuing treatment | 1 | 0 / 115 | 4 / 115 (6.1) | -3 [-7; 0] | 0.11 [0.01; 2.04] | 72 weeks
(J) Combined interferon alfa-2b and lamivudine
Adverse Event | Number of Studies | Treatment n / N (%) | Control n / N (%) | Absolute Risk Difference [95% CI] | Relative Risk Ratio [95% CI] | Trial(s) Duration
Versus placebo, subjects refractory; interferon therapy ^47^
Abnormal ALT/AST | 1 | 6 / 63 (9.5) | 5 / 56 (8.9) | 1 [-10; 11] | 1.07 [0.34; 3.31] | 68 weeks
Abnormal enzymes | 1 | 5 / 63 (7.9) | 2 / 56 (3.6) | 4 [-4; 13] | 2.22 [0.45; 11.0]
Decreased WBCs | 1 | 10 / 63 (15.9) | 5 / 56 (8.9) | 7 [-5; 19] | 1.78 [0.65; 4.89]
Versus placebo, during treatment (0; week 52), subjects refractory; interferon therapy ^47^
ALT: ≥2 × baseline level | 1 | 30 / 63 (47.6) | 11 / 56 (19.6) | 28 [12; 44] | 2.42 [1.34; 4.37] | 52 weeks
ALT: ≥3 × baseline level | 1 | 13 / 63 (20.6) | 7 / 56 (12.5) | 8 [-5; 21] | 1.65 [0.71; 3.84]
ALT: ≥2 × baseline level and 500 U/I | 1 | 8 / 63 (12.7) | 4 / 56 (7.1) | 6 [-5; 16] | 1.78 [0.57; 5.59]
Versus placebo, post-treatment, subjects refractory; interferon therapy ^47^
ALT: ≥2 × baseline level | 1 | 4 / 53 (7.5) | 7 / 47 (14.9) | -7 [-20; 5] | 0.51 [0.16; 1.62] | 16 weeks post-treatment
ALT: ≥3 × baseline level | 1 | 2 / 53 (3.8) | 4 / 47 (8.5) | -5 [-14; 5] | 0.44 [0.09; 2.31]
ALT: ≥2 × baseline level and 500 U/I | 1 | 1 / 53 (1.9) | 2 / 47 (4.3) | -2 [-9; 4] | 0.44 [0.04; 4.73]
Versus IFN monotherapy, during treatment ^67^
Dose modification | 1 | Approx. 20% | Approx. 20% | | | 16; 24 weeks
Hepatic flares (ALT ≥500 IU/l and > 2 × baseline | 1 | 0 / 75 | 8 / 70 (11.4) | -11 [-19; -4] | 0.05 [0.00; 0.93]
Versus IFN monotherapy, post- treatment ^67^
Hepatic flares (ALT ≥500 IU/l and > 2 × baseline | 1 | 5 / 74 (6.8) | 6 / 68 (8.8) | -2 [-11; 7] | 0.77 [0.24; 2.39] | 40 weeks post-treatment
Hepatic flares associated with bilirubin >2 ULN | 1 | 0 | 1 subject
Yalcin 2003^79^ No elevations of serum amylase or creatinine phosphokinase levels observed. No patient required dose reduction or interruption of therapy
Mutimer 1998^80^, 16 weeks interferon plus 12 or 16 weeks lamivudine, subjects refractory interferon therapy
ALT > 10 ULN | 1 | 1 / 20 (5) | During treatment (weeks 6–16), both groups combined
1 | 2 / 20 (10) | 4–16 weeks post-treatment, both groups combined
Creatinine phosphokinase (CPK) elevation | 1 | 8 / 20 (40) | During treatment (weeks 6–16), both groups combined
1 | 12 / 20 (60) | 4–16 weeks post-treatment, both groups combined
CPK > 3 ULN | 1 | 0 / 20 | During treatment (weeks 6–16), both groups combined
| 1 | 2 / 20 (10) | 4–16 weeks post-treatment, both groups combined
Amylase elevation | 1 | 5 / 20 (25) | During treatment (weeks 6–16), both groups combined
1 | 6 / 20 (30) | 4–16 weeks post-treatment, both groups combined
(K) Interferon alfa-2b monotherapy ([underlined: interferon)]
Adverse Event | Number of Studies | Treatment n / N (%) | Control n / N (%) | Absolute Risk Difference [95% CI] | Relative Risk Ratio [95% CI] | Trial(s) Duration
Chung 2003^82^ Prolonged individualized versus 6 months treatment (all subjects combined, N=65). Leucopenia 4 subjects (6.2%) and thrombocytopenia 4 subjects (6.2%).
Janssen 1999^83^ Prolonged (32 weeks) versus standard (16 weeks) duration. Phase A - all subjects prior; randomization (n=162), one case of thrombocytopenia occurred’ leading; dose modification.
Versus no treatment
Lopez-Alcorocho 1997^85^ 6 months (n=19) versus 12 months (n=19). No dose modification needed.
Hadziyannis 1990^88^ IFN (n=25) versus no treatment (n=25). Study duration was 52 weeks. Two subjects in the IFN group required temporary dose reduction due; thrombocytopenia and neutropenia.

ALT = Alanine aminotranferase

AST= Aspartate aminotranferase

ULN= Upper limit of normal

Table E9 Evidence tables of the effects of drug interventions on outcomes among patient subgroups (individual RCTs)

Author Treatments Daily Dose (MU for IFN and mg for RTI) | Length of Treatment in Active/Control Groups | Outcome | Definition of Predicting Variable | Relative Risk (95% CI) | Risk Difference (95% CI) | Number Needed to Treat
Age
Jang, 2004^65^ Interferon Alfa 2b, 2+Lamivudine, 100 vs. Lamivudine, 100 | 176/174 | Viral breakthrough as the reappearance of serum HBV-DNA by solution hybridization assay in at least 2 consecutive tests during lamivudine therapy following the disappearance of the serum HBV DNA | Age:1 year increase | 1.00 (1.00; 1.00)
Bonino, 2007^114^ Peginterferon alfa-2a, 26 vs. Lamivudine, 100 | 48/48 | Adjusted odds ratios of sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | Age: 10 year decrease | 1.30 (1.00; 1.70)
Bonino, 2007^114^ Peginterferon alfa-2a, 26 vs. Lamivudine, 100 | 48/48 | Adjusted odds ratios of sustained combined response at 1 year of followup | Age: 10 year increase | 0.80 (0.63; 1.02)
Adjusted odds ratios of sustained combined response | Age: 10 year decrease | 1.26 (1.00; 1.50)
Bonino, 2007^114^ Peginterferon alfa-2a, 26 + Lamivudine, 100 vs. Lamivudine, 100 | 48/48 | Sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | Age >40 years | 1.61 (0.97; 2.68) | 0.13 (0.00; 0.25) | 8
Age <40 years | 1.66 (1.09; 2.52) | 0.17 (0.04; 0.31) | 6
Bonino, 2007^114^ Peginterferon alfa-2a, 26 +Placebo vs. Lamivudine, 100 | 48/48 | Sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | Age >40 years | 1.59 (0.96; 2.65) | 0.12 (-0.01; 0.25) | 8
Age <40 years | 1.50 (0.97; 2.31) | 0.13 (-0.01; 0.26) | 8
Zhao, 2007^81^ Peginterferon alfa-2b, 11 vs. Interferon Alfa 2b, 1 | 24/24 | Multivariate adjusted odds ratio of Sustained combined response: HBeAg negative, HBV DNA <5 log10 copies/mL, and normal ALT level | Age >25 years vs. <25 years | 0.39 (0.16; 0.92)
Baseline ALT level
Jang, 2004^65^ Interferon Alfa 2b, 2+Lamivudine, 100 vs. Lamivudine, 100 | 176/174 | Viral breakthrough as the reappearance of serum HBV-DNA by solution hybridization assay in at least 2 consecutive tests during lamivudine therapy following the disappearance of the serum HBV DNA | Baseline ALT | 1.00 (1.00; 1.00)
Zarski, 1994^91^ Interferon Alfa 2b, 2+Prednisone, 40 vs. Interferon Alfa 2b, 2 | 24/24 | Chronic active hepatitis | Baseline ALT<3ULN | 0.81 (0.22; 2.91) | -0.03 (-0.22; 0.15) | -32
Zarski, 1994^91^ Interferon Alfa 2b, 2+Prednisone, 40 vs. Interferon Alfa 2b, 2 | 24/24 | Cirrhosis | Baseline ALT<3ULN | 0.40 (0.04; 4.19) | -0.05 (-0.17; 0.08) | -21
Sustained clearance of HBV DNA during therapy + HBeAg seroconversion during or after therapy | Baseline ALT<3ULN | 1.34 (0.36; 5.09) | 0.04 (-0.14; 0.22) | 24
Zarski, 1994^91^ Interferon Alfa 2b, 2+Prednisone, 40 vs. Interferon Alfa 2b, 2 | 24/24 | Sustained clearance of HBV DNA during therapy | Baseline ALT<3ULN | 2.42 (0.27; 21.86) | 0.06 (-0.07; 0.19) | 18
HBsAg loss | Baseline ALT<3ULN | 3.23 (0.38; 27.06) | 0.09 (-0.05; 0.23) | 11
Perrillo, 2002^104^ Interferon Alfa 2b, 4 vs. Lamivudine, 100 | 24/24 | HBeAg loss irrespective of HBV-DNA status at baseline or week 25 | Baseline ALT >5ULN | 0.68 (0.25; 1.86) | -0.03 (-0.09; 0.03) | -37
Perrillo, 2002^104^ Interferon Alfa 2b, 4 vs. Lamivudine, 100 | 24/24 | HBeAg seroconversion and HBV DNA loss | Baseline ALT >5ULN | 0.72 (0.22; 2.31) | -0.02 (-0.07; 0.04) | -57
Perrillo, 2002^104^ Interferon Alfa 2b, 4 vs. Lamivudine, 100 | 24/24 | HBeAg loss irrespective of HBV-DNA status at baseline or week 34 | Baseline ALT >2-≤5ULN | 0.89 (0.42; 01.89) | -0.01 (-0.09; 0.07) | -78
Perrillo, 2002^104^ Interferon Alfa 2b, 4 vs. Lamivudine, 100 | 24/24 | HBeAg seroconversion and HBV DNA loss | Baseline ALT >2-≤5ULN | 1.12 (0.49; 2.58) | 0.01 (-0.06; 0.08) | 106
Perrillo, 2002^104^ Interferon Alfa 2b, 4 vs. Lamivudine, 100 | 24/24 | HBeAg loss irrespective of HBV-DNA status | Baseline ALT >1-≤2ULN | 1.00 (0.30; 3.29) | 0.00 (-0.05; 0.05) | -4602
Perrillo, 2002^104^ Interferon Alfa 2b, 4 vs. Lamivudine, 100 | 24/24 | HBeAg seroconversion and HBV DNA loss | Baseline ALT >1-≤2ULN | 1.49 (0.32; 6.88) | 0.01 (-0.03; 0.05) | 103
Perrillo, 2002^104^ Interferon Alfa 2b, 4 vs. Lamivudine, 100 | 24/24 | HBeAg loss irrespective of HBV-DNA status at baseline or week 52 | Baseline ALT ≤1ULN | 2.99 (0.27; 32.47) | 0.01 (-0.02; 0.04) | 102
HBeAg seroconversion and HBV DNA loss | Baseline ALT ≤1ULN | 5.97 (0.38; 94.32) | 0.01 (-0.02; 0.04) | 82
Schalm, 2000^67^ Interferon Alfa 2b, 4 vs. Lamivudine, 100 | 24/52 | HBeAg seroconversion and undetectable HBV DNA | Baseline ALT 5 ULN | 0.85 (0.40; 1.79) | -0.03 (-0.14; 0.09) | -39
Schalm, 2000^67^ Interferon Alfa 2b, 4 vs. Lamivudine, 100 | 24/52 | HBeAg seroconversion and undetectable HBV DNA | Baseline ALT 2–5 ULN | 1.02 (0.71; 1.47) | 0.01 (-0.15; 0.17) | 126
HBeAg seroconversionand undetectable HBV DNA | Baseline ALT 2 ULN | 0.92 (0.60; 1.41) | -0.03 (-0.18; 0.12) | -33
Perrillo, 2002^104^ Interferon Alfa 2b, 4 +Lamivudine, 100 vs. Interferon Alfa 2b, 4 | 24/24 | HBeAg loss irrespective of HBV-DNA status at baseline or week 25 | Baseline ALT >5ULN | 1.26 (0.41; 3.87) | 0.02 (-0.06; 0.09) | 66
Perrillo, 2002^104^ Interferon Alfa 2b, 4 +Lamivudine, 100 vs. Interferon Alfa 2b, 4 | 24/24 | HBeAg seroconversion and HBV DNA loss | Baseline ALT >5ULN | 1.51 (0.42; 5.40) | 0.02 (-0.04; 0.09) | 44
Perrillo, 2002^104^ Interferon Alfa 2b, 4 +Lamivudine, 100 vs. Interferon Alfa 2b, 4 | 24/24 | HBeAg loss irrespective of HBV-DNA status at baseline or week 34 | Baseline ALT >2-≤5ULN | 1.30 (0.57; 2.95) | 0.03 (-0.06; 0.12) | 33
Perrillo, 2002^104^ Interferon Alfa 2b, 4 +Lamivudine, 100 vs. Interferon Alfa 2b, 4 | 24/24 | HBeAg seroconversion and HBV DNA loss | Baseline ALT >2-≤5ULN | 1.09 (0.43; 2.75) | 0.01 (-0.08; 0.09) | 124
Perrillo, 2002^104^ Interferon Alfa 2b, 4 +Lamivudine, 100 vs. Interferon Alfa 2b, 4 | 24/24 | HBeAg loss irrespective of HBV-DNA status at baseline or week 43 | Baseline ALT >1-≤2ULN | 1.18 (0.31; 4.40) | 0.01 (-0.05; 0.07) | 129
Perrillo, 2002^104^ Interferon Alfa 2b, 4 +Lamivudine, 100 vs. Interferon Alfa 2b, 4 | 24/24 | HBeAg seroconversion and HBV DNA loss | Baseline ALT >1-≤2ULN | 1.26 (0.25; 6.32) | 0.01 (-0.04; 0.06) | 131
Perrillo, 2002^104^ Interferon Alfa 2b, 4 +Lamivudine, 100 vs. Interferon Alfa 2b, 4 | 24/24 | HBeAg loss irrespective of HBV-DNA status at baseline or week 52 | Baseline ALT ≤1ULN | 0.17 (0.01; 4.10) | -0.01 (-0.05; 0.02) | -68
HBeAg seroconversion and HBV DNA loss | Baseline ALT ≤1ULN | 0.17 (0.01; 4.10) | -0.01 (-0.05; 0.02) | -68
Schalm, 2000^67^ Interferon Alfa 2b, 4 +Lamivudine, 100 vs. Interferon Alfa 2b, 4 | 24/24 | HBeAg seroconversionand undetectable HBV DNA | Baseline ALT >5 ULN | 0.92 (0.41; 2.07) | -0.01 (-0.12; 0.10) | -86
Schalm, 2000^67^ Interferon Alfa 2b, 4 +Lamivudine, 100 vs. Interferon Alfa 2b, 4 | 24/24 | HBeAg seroconversionand undetectable HBV DNA | ALT 2–5 ULN | 0.95 (0.65; 1.39) | -0.02 (-0.18; 0.14) | -47
ALT <2 ULN | 1.04 (0.67; 1.61) | 0.01 (-0.14; 0.17) | 82
Barbaro, 2001^66^ Interferon Alfa 2b, 4 + Lamivudine, 100 vs. Lamivudine, 100 | 24/52 | Odds Ratio of sustained virologic response (sustained suppression of serum levels of HBeAg and HBV DNA) in those with baseline ALT levels of 150 or more independent on gender and age | Baseline ALT | 3.12 (1.43; 6.82)
Perrillo, 2002^104^ Interferon Alfa 2b, 4 +Lamivudine, 100 vs. Lamivudine, 100 | 24/52 | HBeAg loss irrespective of HBV-DNA status at baseline or week 25 | Baseline ALT >5ULN | 0.86 (0.44; 1.69) | -0.01 (-0.06; 0.04) | -82
Perrillo, 2002^104^ Interferon Alfa 2b, 4 +Lamivudine, 100 vs. Lamivudine, 100 | 24/52 | HBeAg seroconversion and HBV DNA loss | Baseline ALT >5ULN | 1.08 (0.52; 2.26) | 0.01 (-0.04; 0.05) | 196
Perrillo, 2002^104^ Interferon Alfa 2b, 4 +Lamivudine, 100 vs. Lamivudine, 100 | 24/52 | HBeAg loss irrespective of HBV-DNA status at baseline or week 34 | Baseline ALT >2-≤5ULN | 1.15 (0.69; 1.91) | 0.02 (-0.05; 0.08) | 57
Perrillo, 2002^104^ Interferon Alfa 2b, 4 +Lamivudine, 100 vs. Lamivudine, 100 | 24/52 | HBeAg seroconversion and HBV DNA loss | Baseline ALT >2-≤5ULN | 1.22 (0.66; 2.26) | 0.02 (-0.04; 0.07) | 57
Perrillo, 2002^104^ Interferon Alfa 2b, 4 +Lamivudine, 100 vs. Lamivudine, 100 | 24/52 | HBeAg loss irrespective of HBV-DNA status at baseline or week 43 | Baseline ALT >1-≤2ULN | 1.17 (0.50; 2.74) | 0.01 (-0.03; 0.05) | 133
Perrillo, 2002^104^ Interferon Alfa 2b, 4 +Lamivudine, 100 vs. Lamivudine, 100 | 24/52 | HBeAg seroconversion and HBV DNA loss | Baseline ALT >1-≤2ULN | 1.88 (0.63; 5.65) | 0.02 (-0.02; 0.05) | 58
Perrillo, 2002^104^ Interferon Alfa 2b, 4 +Lamivudine, 100 vs. Lamivudine, 100 | 24/52 | HBeAg loss irrespective of HBV-DNA status at baseline or week 52 | Baseline ALT ≤1ULN | 0.60 (0.03; 12.39) | 0.00 (-0.02; 0.01) | -203
HBeAg seroconversion and HBV DNA loss | Baseline ALT ≤1ULN | 1.00 (0.04; 24.34) | 0.00 (-0.01; 0.01) | -406
Schalm, 2000^67^ Interferon Alfa 2b, 4 + Lamivudine, 100 vs. Lamivudine, 100 | 24/52 | HBeAg seroconversionand undetectable HBV DNA | Baseline ALT >5 ULN | 0.78 (0.37; 1.65) | -0.04 (-0.15; 0.07) | -27
Schalm, 2000^67^ Interferon Alfa 2b, 4 + Lamivudine, 100 vs. Lamivudine, 100 | 24/52 | HBeAg seroconversionand undetectable HBV DNA | Baseline ALT 2–5 ULN | 0.97 (0.67; 1.40) | -0.01 (-0.17; 0.14) | -74
Baseline ALT <2 ULN | 0.95 (0.63; 1.43) | -0.02 (-0.17; 0.13) | -55
Lok, 1992^93^ Interferon Alfa 2b, 4 + Prednisone, 15 vs. placebo for 6 weeks + 2 weeks rest than Interferon Alfa 2b, 4 | 24/24 | Partial antiviral response: sustained clearance of serum HBV DNA by direct spot hybridization (lower limit of detection of 10 pg/mL) and clearance of HBeAg but not HBsAg | Elevated baseline ALT | 1.54 (0.63; 03.77) | 0.15 (-0.15; 0.45) | 7
Complete antiviral response: sustained clearance of serum HBV DNA by direct spot hybridization (lower limit of detection of 10 pg/mL) and clearance of HBeAg and HBsAg | Elevated baseline ALT | 0.29 (0.01; 6.66) | -0.06 (-0.19; 0.08) | -18
Wai, 2002^102^ Interferon Alfa 2b, 4 +Prednisone, 15 vs. placebo for 6weeks + 2 weeks rest than Interferon Alfa 2b, 4 | 24/24 | Adjusted for age, gender, baseline ALT, HBV DNA, and histology, precore G1896A mutation, core promoter A1762T, G1764A, and treatment with Interferon with and without prednisone pretreatment odds ratios of antiviral response: as sustained clearance of serum HBV DNA | Elevated baseline ALT | 1.22 (1.05; 1.42)
Perrillo, 1990^96^ Interferon Alfa 2b, 5 vs. Interferon Alfa 2b, 1 | 24/24 | Loss of HBV DNA and HBeAg | Baseline ALT 100–200U/l | 2.00 (0.54; 7.46) | 0.07 (-0.06; 0.21) | 14
Perrillo, 1990^96^ Interferon Alfa 2b, 5 vs. Interferon Alfa 2b, 1 | 24/24 | Loss of HBV DNA and HBeAg | Baseline ALT >200U/l | 2.33 (0.65; 8.40) | 0.10 (-0.04; 0.24) | 10
Loss of HBV DNA and HBeAg | Baseline ALT <100U/l | 2.00 (0.19; 21.21) | 0.02 (-0.06; 0.11) | 41
Perrillo, 1990^96^ Interferon Alfa 2b, 5 + Prednisone, 40 vs. Interferon Alfa 2b, 1 | 24/24 | Loss of HBV DNA and HBeAg | Baseline ALT 100–200U/l | 1.24 (0.30; 5.22) | 0.02 (-0.10; 0.13) | 56
Perrillo, 1990^96^ Interferon Alfa 2b, 5 + Prednisone, 40 vs. Interferon Alfa 2b, 1 | 24/24 | Loss of HBV DNA and HBeAg | Baseline ALT >200U/l | 1.24 (0.30; 5.22) | 0.02 (-0.10; 0.13) | 56
Perrillo, 1990^96^ Interferon Alfa 2b, 5 + Prednisone, 40 vs. Interferon Alfa 2b, 1 | 24/24 | Loss of HBV DNA and HBeAg | Baseline ALT <100U/l | 7.45 (0.97; 57.04) | 0.16 (0.03; 0.28) | 6
Loss of HBV DNA and HBeAg | 24/24 | Baseline ALT 100–200U/l | 0.62 (0.19; 2.04) | -0.06 (-0.19; 0.08) | -18
Interferon Alfa 2b, 5 + Prednisone, 40 vs. Interferon Alfa 2b, 5 | 24/24 | Loss of HBV DNA and HBeAg | Baseline ALT >200U/l | 0.53 (0.17; 1.69) | -0.08 (-0.22; 0.06) | -13
Loss of HBV DNA and HBeAg | Baseline ALT <100U/l | 3.73 (0.84; 16.54) | 0.13 (0.00; 0.26) | 8
Lopez-Alcorocho, 1997^85^ Interferon Alfa 2b, 6 vs. Interferon Alfa 2b, 2 | 24/48 | Increase in ALT above normal | Baseline normal ALT | 13.00 (0.78; 215.69) | 0.32 (0.10; 0.53) | 3
Kim, 2006^54^ Lamivudine, 100 vs. placebo | 80/80 | Odds ratio of hepatic decompensation change in the Child-Turcotte-Pugh score of 2 or more points adjusted for treatments, ALT, HBV DNA, sex, YMDD variant, platelet, bilirubin, albumin | Higher Baseline ALT | 1.01 (01.00; 01.01)
Liaw, 2004^51^ Lamivudine, 100 vs. placebo | 130/130 | Overall disease progression by the first occurrence of any of the following: an increase of at least 2 points in the Child-Pugh score (an assessment of the severity of liver disease [range, 5 to 15, where 5 indicates good and 15 - poor liver function] | Baseline ALT ≤2 times the upper limit of normal | 0.53 (0.32; 0.89) | -0.05 (-0.10; -0.01) | -18
Baseline ALT >2 times the upper limit of normal | 0.27 (0.11; 0.66) | -0.04 (-0.08; -0.01) | -23
Liaw, 2000^110^ Lamivudine, 100 vs. Lamivudine, 25 | 104/104 | Sustained HBeAg Seroconversion | Baseline ALT > 5X ULN | 1.09 (0.42; 02.78) | 0.01 (-0.07; 0.08) | 147
Liaw, 2000^110^ Lamivudine, 100 vs. Lamivudine, 25 | 104/104 | Baseline ALT 2–5X ULN | 1.09 (0.49; 02.39) | 0.01 (-0.08; 0.10) | 107
Liaw, 2000^110^ Lamivudine, 100 vs. Lamivudine, 25 | 104/104 | HBeAg Seroconversion | Baseline ALT 2–5X ULN | 1.09 (0.67; 01.75) | 0.02 (-0.10; 0.14) | 47
Liaw, 2000^110^ Lamivudine, 100 vs. Lamivudine, 25 | 104/104 | Sustained HBeAg Seroconversion | Baseline ALT 1–2X ULN | 0.87 (0.24; 03.14) | -0.01 (-0.07; 0.05) | -154
Baseline ALT <3X ULN | 2.17 (0.20; 23.56) | 0.01 (-0.02; 0.05) | 86
Bonino, 2007^114^ Peginterferon alfa-2a, 26 vs. Lamivudine, 100 | 48/48 | Adjusted odds ratios of sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | Baseline ALT: 1 log 10 unit (IU/l) increase | 4.00 (2.00; 8.00)
Baseline ALT | 1.00 (1.00; 1.00)
Bonino, 2007^114^ Peginterferon alfa-2a, 26 + Lamivudine, 100 vs. Lamivudine, 100 | 48/48 | Sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | Baseline ALT >5 ULN | 1.40 (0.73; 2.70) | 0.13 (-0.12; 0.39) | 8
Bonino, 2007^114^ Peginterferon alfa-2a, 26 + Lamivudine, 100 vs. Lamivudine, 100 | 48/48 | Sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | Baseline ALT >2–5 ULN | 1.43 (0.83; 2.45) | 0.10 (-0.05; 0.24) | 11
Baseline ALT<2 ULN | 1.84 (1.11; 3.02) | 0.18 (0.04; 0.32) | 5
Cindoruk, 2007^115^ Peginterferon alfa-2a, 26 + Lamivudine, 100 vs. Lamivudine, 100 | 9/9 | Adjusted for treatment status odds ratio of sustained response: HBeAg seroconversion, HBV DNA disappearance and ALT normalization in HBeAg (+) patients. In HBeAg (-) patients: loss of HBV DNA, ALT normalization | Baseline ALT (IU/L) | 10.32 (9.71; 10.97)
Lau, 2005^56^ Peginterferon alfa-2a, 26 + Lamivudine, 100 vs. Lamivudine, 100 | 48/48 | HBeAg seroconversion | Baseline ALT ≤2ULN | 1.00 (0.54; 1.85) | 0.00 (-0.04; 0.04) | 3879
Lau, 2005^56^ Peginterferon alfa-2a, 26 + Lamivudine, 100 vs. Lamivudine, 100 | 48/48 | HBeAg seroconversion | Baseline ALT >2 to 5 ULN | 1.51 (0.88; 2.58) | 0.04 (-0.01; 0.09) | 27
Baseline ALT > 5ULN | 1.93 (1.01; 3.69) | 0.04 (0.00; 0.09) | 22
Lau, 2005^56^ Peginterferon alfa-2a, 26 + Lamivudine, 100 vs. peginterferon alfa-2a, 26 | 48/48 | HBeAg seroconversion | Baseline ALT ≤2ULN | 0.70 (0.40; 1.23) | -0.03 (-0.08; 0.02) | -34
Lau, 2005^56^ Peginterferon alfa-2a, 26 + Lamivudine, 100 vs. peginterferon alfa-2a, 26 | 48/48 | HBeAg seroconversion | Baseline ALT >2 to 5 ULN | 0.83 (0.53; 1.31) | -0.02 (-0.08; 0.03) | -45
Baseline ALT > 5ULN | 1.04 (0.61; 1.78) | 0.00 (-0.04; 0.05) | 271
Bonino, 2007^114^ Peginterferon alfa-2a, 26 + placebo, vs. Lamivudine, 100 | 48/48 | Sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | Baseline ALT>5ULN | 1.44 (0.74; 2.82) | 0.15 (-0.12; 0.41) | 7
Bonino, 2007^114^ Peginterferon alfa-2a, 26 + placebo, vs. Lamivudine, 100 | 48/48 | Sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | Baseline ALT>2–5ULN | 1.65 (0.96; 2.84) | 0.14 (-0.01; 0.28) | 7
Baseline ALT<2ULN | 1.49 (0.89; 2.52) | 0.11 (-0.03; 0.24) | 9
Lau, 2005^56^ Peginterferon alfa-2a, 26 + placebo, vs. Lamivudine, 100 | 48/48 | HBeAg Seroconversion | Baseline ALT ≤2ULN | 1.43 (0.81; 2.50) | 0.03 (-0.02; 0.08) | 34
Lau, 2005^56^ Peginterferon alfa-2a, 26 + placebo, vs. Lamivudine, 100 | 48/48 | HBeAg Seroconversion | Baseline ALT >2 to 5 ULN | 1.81 (1.07; 3.04) | 0.06 (0.01; 0.11) | 17
Baseline ALT > ULN | 1.85 (0.96; 3.56) | 0.04 (0.00; 0.08) | 25
Zhao, 2007^81^ Peginterferon alfa-2b, 11 vs. Interferon Alfa 2b, 1 | 24/24 | Multivariate adjusted odds ratio of sustained combined response: HBeAg negative, HBV DNA <5 log10 copies/mL, and normal ALT level | Baseline ALT level >3.4 vs. <3.4 ULN | 1.23 (0.51; 2.92)
Chan, 2005^59^ Peginterferon alfa-2b, 14 + Lamivudine, 100 vs. Lamivudine, 100 | 60/52 | Sustained virological response as HBeAg seroconversion and HBV DNA <500,000 copies/mL | Baseline ALT levels less than 5 times the upper limit of normal | 2.08 (1.18; 3.67) | 0.26 (0.08; 0.44) | 4
Chan, 2005^59^ Peginterferon alfa-2b, 14 + Lamivudine, 100 vs. Lamivudine, 100 | 60/52 | Adjusted for treatment allocation, HBV genotype and log HBV DNA odds ratio of persistent HBeAg loss and had less than two occasions with HBV DNA <100,000 copies/mL at any time up to week 76 of post-treatment followup | Baseline ALT | 1.00 (0.99; 1.00)
Adjusted for treatment allocation, HBV DNA genotype, IL-1b-511 polymorphism, baseline log HBV DNA odds ratio of persistent HBeAg loss and had less than two occasions with HBV DNA <100 000 copies/mL | Baseline ALT | 1.00 (0.99; 1.00)
Flink, 2005^120^ Peginterferon alfa-2b, 14 + Lamivudine, 100 vs. peginterferon alfa-2b, 14 | 52/52 | Adjusted relative risk of flares defined as an increase in serum ALT to at least three times the baseline level | Lower ALT at baseline | 1.40 (1.20; 1.60)
Janssen, 2005^78^ Peginterferon alfa-2b, 14 + Lamivudine, 100 vs. peginterferon alfa-2b, 14 | 52/52 | Adjusted odds ratio of Sustained HBeAg loss | Higher baseline ALT | 1.10 (1.00; 1.20)
Baseline histological activity
Jang, 2004^65^ Interferon Alfa 2b, 2 + Lamivudine, 100 vs. Lamivudine, 100 | 176/174 | Viral breakthrough as the reappearance of serum HBV-DNA by solution hybridization assay in at least 2 consecutive tests during lamivudine therapy following the disappearance of the serum HBV DNA | Histological activity | 1.00 (1.00; 1.00)
Extent of fibrosis | 1.00 (1.00; 1.00)
Perrillo, 2002^104^ Interferon Alfa 2b, 4 vs. Lamivudine, 100 | 24/24 | HBeAg loss of detectable levels of HBeAg in serum irrespective of HBV-DNA status at baseline or week 56 | Pretreatment HAI Score 5–9 | 1.43 (0.61; 3.36) | 0.03 (-0.04; 0.10) | 38
Perrillo, 2002^104^ Interferon Alfa 2b, 4 vs. Lamivudine, 100 | 24/24 | HBeAg loss of detectable levels of HBeAg in serum irrespective of HBV-DNA status at baseline or week 56 | Pretreatment HAI Score 0–4 | 2.65 (0.84; 8.38) | 0.04 (-0.02; 0.09) | 27
Pretreatment HAI Score >10 | 0.49 (0.20; 1.17) | -0.08 (-0.15; -0.01) | -13
Perrillo, 2002^104^ Interferon Alfa 2b, 4 + Lamivudine, 100 vs. Interferon Alfa 2b, 4 | 24/24 | HBeAg loss of detectable levels of HBeAg in serum irrespective of HBV-DNA status at baseline or week 56 | Pretreatment HAI Score 5–9 | 0.92 (0.36; 2.39) | -0.01 (-0.09; 0.07) | -148
Perrillo, 2002^104^ Interferon Alfa 2b, 4 + Lamivudine, 100 vs. Interferon Alfa 2b, 4 | 24/24 | HBeAg loss of detectable levels of HBeAg in serum irrespective of HBV-DNA status at baseline or week 56 | Pretreatment HAI Score 0–4 | 0.88 (0.27; 2.91) | -0.01 (-0.07; 0.06) | -143
Pretreatment HAI Score >10 | 1.61 (0.62; 4.21) | 0.04 (-0.04; 0.13) | 22
Barbaro, 2001^66^ Interferon Alfa 2b, 4 + Lamivudine, 100 vs. Lamivudine, 100 | 24/52 | Odds Ratio of sustained virologic response (sustained suppression of serum levels of HBeAg and HBV DNA) in those with a baseline inflammation score of 7 or more independent on gender and age | Baseline inflammation score | 2.91 (1.04; 8.22)
Odds Ratio of sustained virologic response (sustained suppression of serum levels of HBeAg and HBV DNA) in those with a baseline fibrosis score of 2 or more independent on gender and age | baseline fibrosis score | 2.58 (0.88; 7.60)
Perrillo, 2002^104^ Interferon Alfa 2b, 4 + Lamivudine, 100 vs. Lamivudine, 100 | 24/52 | HBeAg loss of detectable levels of HBeAg in serum irrespective of HBV-DNA status at baseline or week 56 | Pretreatment HAI Score 5–9 | 1.32 (0.67; 2.62) | 0.02 (-0.03; 0.07) | 50
Perrillo, 2002^104^ Interferon Alfa 2b, 4 + Lamivudine, 100 vs. Lamivudine, 100 | 24/52 | HBeAg loss of detectable levels of HBeAg in serum irrespective of HBV-DNA status at baseline or week 56 | Pretreatment HAI Score 0–4 | 2.34 (0.89; 6.16) | 0.03 (-0.01; 0.07) | 34
Pretreatment HAI Score >10 | 0.79 (0.47; 1.32) | -0.03 (-0.10; 0.03) | -32
Liaw, 2004^51^ Lamivudine, 100 vs. placebo | 130/130 | Overall disease progression by an increase of at least 2 points in the Child-Pugh score | Ishak fibrosis score = 6 | 0.37 (0.19; 0.71) | -0.06 (-0.10; -0.02) | -17
Liaw, 2004^51^ Lamivudine, 100 vs. placebo | 130/130 | Overall disease progression by an increase of at least 2 points in the Child-Pugh score | Ishak fibrosis score = 5 | 0.60 (0.25; 1.43) | -0.02 (-0.05; 0.01) | -60
Liaw, 2004^51^ Lamivudine, 100 vs. placebo | 130/130 | Overall disease progression by an increase of at least 2 points in the Child-Pugh score | Ishak fibrosis score <4 | 0.44 (0.17; 1.12) | -0.02 (-0.05; 0.01) | -43
Liaw, 2004^51^ Lamivudine, 100 vs. placebo | 130/130 | Overall disease progression by an increase of at least 2 points in the Child-Pugh score | Baseline Child-Pugh score >7 | 0.55 (0.22; 1.42) | -0.02 (-0.05; 0.01) | -60
Liaw, 2004^51^ Lamivudine, 100 vs. placebo | 130/130 | Overall disease progression by an increase of at least 2 points in the Child-Pugh score | Baseline Child-Pugh score = 6 | 0.37 (0.16; 0.86) | -0.04 (-0.07; 0.00) | -28
Baseline Child-Pugh score = 5 | 0.44 (0.23; 0.84) | -0.05 (-0.09; -0.01) | -21
Lai, 1998^50^ Lamivudine, 25 vs. Lamivudine, 100 | 48/48 | Worsening of Knodell necroinflammatory score | Patients with moderate or severe hepatitis | 2.52 (0.50; 12.76) | 0.02 (-0.01; 0.06) | 47
Lai, 1998^50^ Lamivudine, 25 vs. Lamivudine, 100 | 48/48 | Histological response -a reduction of 2 or more points in the Knodell necroinflammatory score (components 1 through 3) between baseline and week 52 | Patients with moderate or severe hepatitis | 0.94 (0.72; 1.23) | -0.03 (-0.14; 0.09) | -40
Lai, 1998^50^ Lamivudine, 25 vs. Lamivudine, 100 | 48/48 | Worsening of Knodell necroinflammatory score | Patients with mild hepatitis | 0.88 (0.33; 2.37) | -0.01 (-0.06; 0.05) | -150
Histological response -a reduction of 2 or more points in the Knodell necroinflammatory score (components 1 through 3) between baseline and week 52 | Patients with mild hepatitis | 0.65 (0.32; 1.34) | -0.04 (-0.11; 0.03) | -24
Cindoruk, 2007^115^ Peginterferon alfa-2a, 26 + Lamivudine, 100 vs. Lamivudine, 100 | 9/9 | Adjusted for treatment status odds ratio of sustained response: HBeAg seroconversion, HBV DNA disappearance and ALT normalization in HBeAg (+) patients. In HBeAg (-) patients: loss of HBV DNA, ALT normalization | Presence of steatosis | 1.00 (1.00; 1.00)
Baseline Knodell HAI | 14.97 (2.43; 92.28)
Flink, 2005^120^ Peginterferon alfa-2b, 14 + Lamivudine, 100 vs. peginterferon alfa-2b, 14 | 52/52 | Adjusted relative risk of Flares defined as an increase in serum ALT to at least 3 times the baseline level | Preexisting cirrhosis, yes vs. no | 2.00 (1.00; 4.00)
Buster, 2007^124^ Peginterferon alfa-2b, 14 + Lamivudine, 100 vs. peginterferon alfa-2b, 14 | 52/52 | Adjusted relative risk of HBeAg seroconversion and HBV DNA <10,000 copies/ml | Presence of advanced fibrosis- fibrosis score of 4–6 (HAI) | 0.98 (0.17; 05.23)
Baseline viral load
Jang, 2004^65^ Interferon Alfa 2b, 2 + Lamivudine, 100 vs. Lamivudine, 100 | 176/174 | Viral breakthrough as the reappearance of serum HBV-DNA by solution hybridization assay in at least 2 consecutive tests during lamivudine therapy following the disappearance of the serum HBV DNA | Baseline HBV-DNA | 1.00 (1.00; 1.00)
Barbaro, 2001^66^ Interferon Alfa 2b, 4 + Lamivudine, 100 vs. Lamivudine, 100 | 24/52 | Odds ratio of sustained virologic response (sustained suppression of serum levels of HBeAg and HBV DNA) in those with baseline viral load of 200 pg/ml or less independent on gender and age | Baseline HBV DNA | 7.23 (2.71; 19.57)
Wai, 2002^102^ Interferon Alfa 2b, 4 + Prednisone, 15 vs. placebo for 6weeks + 2 weeks rest than Interferon Alfa 2b, 4 | 24/24 | Adjusted for age, gender, baseline ALT, HBV DNA, and histology, precore G1896A mutation, core promoter A1762T, G1764A, and treatment with Interferon with and without prednisone pretreatment odds ratios of antiviral response: as sustained clearance of serum HBV DNA | Low baseline HBV-DNA level | 1.10 (1.03; 1.17)
Low baseline HBV-DNA in patients with elevated baseline ALT | 1.10 (1.01; 1.21)
Perrillo, 1990^96^ Interferon Alfa 2b, 5 vs. Interferon Alfa 2b, 1 | 24/24 | Loss of HBV DNA and HBeAg | Baseline HBV DNA 2-99pg/ml | 1.67 (0.67; 4.16) | 0.10 (-0.07; 0.27) | 10
Perrillo, 1990^96^ Interferon Alfa 2b, 5 vs. Interferon Alfa 2b, 1 | 24/24 | Loss of HBV DNA and HBeAg | Baseline HBV DNA 100–200 pg/ml | 11.00 (0.63; 192.71) | 0.12 (0.01; 0.23) | 8
Baseline HBV DNA >200 pg/ml | 0.33 (0.01; 07.95) | -0.02 (-0.09; 0.04) | -41
Sarin, 2005^69^ Interferon Alfa 2b, 5 + Lamivudine, 100 vs. Lamivudine, 100 | 52/52 | HBV DNA loss and HBeAg seroconversion | Baseline HBV DNA >107 copies/mL | 2.92 (0.63; 13.56) | 0.10 (-0.03; 0.24) | 10
Sarin, 2005^69^ Interferon Alfa 2b, 5 + Lamivudine, 100 vs. Lamivudine, 100 | 52/76 | 4.87 (1.14; 20.74) | 0.21 (0.05; 0.37) | 5
Sarin, 2005^69^ Interferon Alfa 2b, 5 + Lamivudine, 100 vs. Lamivudine, 100 | 52/52 | HBeAg loss | Baseline HBV DNA >107 copies/mL | 1.62 (0.66; 4.01) | 0.10 (-0.08; 0.28) | 10
Sarin, 2005^69^ Interferon Alfa 2b, 5 + Lamivudine, 100 vs. Lamivudine, 100 | 52/76 | 3.89 (1.20; 12.69) | 0.23 (0.06; 0.41) | 4
Sarin, 2005^69^ Interferon Alfa 2b, 5 + Lamivudine, 100 vs. Lamivudine, 100 | 52/52 | HBeAg loss with anti-HBe appearance | Baseline HBV DNA >107 copies/mL | 2.92 (0.63; 13.56) | 0.10 (-0.03; 0.24) | 10
52/76 | 4.87 (1.14; 20.74) | 0.21 (0.05; 0.37) | 5
Perrillo, 1990^96^ Interferon Alfa 2b, 5 + Prednisone, 40 vs. Interferon Alfa 2b, 1 | 24/24 | Loss of HBV DNA and HBeAg | Baseline HBV DNA 2-99 pg/ml | 1.71 (0.70; 4.20) | 0.10 (-0.06; 0.27) | 10
Perrillo, 1990^96^ Interferon Alfa 2b, 5 + Prednisone, 40 vs. Interferon Alfa 2b, 1 | 24/24 | Loss of HBV DNA and HBeAg | Baseline HBV DNA 100–200 pg/ml | 8.40 (0.47; 151.34) | 0.09 (0.00; 0.18) | 11
Baseline HBV DNA >200 pg/ml | 0.93 (0.06; 14.42) | 0.00 (-0.07; 0.06) | -601
Interferon Alfa 2b, 5 + Prednisone, 40 vs. Interferon Alfa 2b, 5 | | Loss of HBV DNA and HBeAg | Baseline HBV DNA 2-99 pg/ml | 1.03 (0.49; 2.16) | 0.01 (-0.18; 0.19) | 164
Interferon Alfa 2b, 5 + Prednisone, 40 vs. Interferon Alfa 2b, 5 | | Loss of HBV DNA and HBeAg | Baseline HBV DNA 100–200 pg/ml | 0.75 (0.21; 2.59) | -0.03 (-0.16; 0.10) | -32
Baseline HBV DNA >200 pg/ml | 2.80 (0.12; 66.85) | 0.02 (-0.04; 0.08) | 44
Kim, 2006^54^ Lamivudine, 100 vs. placebo | 80/80 | Odds ratio of hepatic decompensation change in the Child-Turcotte-Pugh score of 2 or more points adjusted for treatments, ALT, HBV DNA, sex, YMDD variant, platelet, bilirubin, albumin | Baseline platelet count less vs. >65 000/μl | 0.98 (0.97; 0.99)
Baseline HBV DNA | 1.00 (1.00; 1.00)
Liaw, 2004^51^ Lamivudine, 100 vs. Placebo | 130/130 | Overall disease progression | Baseline HBV DNA below the lower limit of quantitation | 0.22 (0.07; 0.70) | -0.03 (-0.06; 0.00) | -31
Liaw, 2004^51^ Lamivudine, 100 vs. Placebo | 130/130 | Overall disease progression | Baseline HBV DNA 0.7–10 meq/ml | 0.77 (0.34; 1.74) | -0.01 (-0.04; 0.02) | -103
Liaw, 2004^51^ Lamivudine, 100 vs. Placebo | 130/130 | Overall disease progression | Baseline HBV DNA >10–100 meq/ml | 0.37 (0.13; 1.05) | -0.02 (-0.05; 0.00) | -43
Baseline HBV DNA >100 meq/ml | 0.41 (0.18; 0.94) | -0.03 (-0.07; 0.00) | -30
Bonino, 2007^114^ Peginterferon alfa-2a, 26 vs. Lamivudine, 100 | 48/48 | Adjusted odds ratios of sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | Baseline HBV DNA, per 1 log decrease | 1.20 (1.00; 1.40)
Bonino, 2007^114^ Peginterferon alfa-2a, 26 vs. Lamivudine, 100 | 48/48 | Adjusted odds ratios of sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | Log10 HBV DNA (baseline) | 1.06 (0.93; 1.21)
HBV DNA:1 log10 unit (copies/ml) decrease | 1.28 (1.10; 1.40)
Cindoruk, 2007^115^ Peginterferon alfa-2a, 26 + Lamivudine, 100 vs. Lamivudine, 100 | 9/9 | Adjusted for treatment status odds ratio of sustained response: HBeAg seroconversion, HBV DNA disappearance and ALT normalization in HBeAg (+) patients. In HBeAg (-) patients: loss of HBV DNA, ALT normalization | Baseline mean viral load (copy/mL) | 1.05 (0.13; 8.14)
Bonino, 2007^114^ Peginterferon alfa-2a, 26 + Lamivudine, 100 vs. Lamivudine, 100 | 48/48 | Sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | Baseline HBV DNA >8.42 log 10 copies/ml | 1.37 (0.67; 2.80) | 0.08 (-0.10; 0.26) | 12
Bonino, 2007^114^ Peginterferon alfa-2a, 26 + Lamivudine, 100 vs. Lamivudine, 100 | 48/48 | Sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | Baseline HBV DNA >6.12–8.42 log 10 copies/ml | 1.78 (1.11; 2.84) | 0.17 (0.04; 0.29) | 6
Baseline HBV DNA <6.12 log 10 copies/ml | 2.24 (1.31; 3.83) | 0.35 (0.13; 0.57) | 3
Lau, 2005^56^ Peginterferon alfa-2a, 26 + Lamivudine, 100 vs. Lamivudine, 100 | 48/48 | HBeAg Seroconversion | Baseline HBV DNA levels>10.26 (log copies/ml) | 2.01 (0.82; 4.90) | 0.03 (-0.01; 0.06) | 39
Lau, 2005^56^ Peginterferon alfa-2a, 26 + Lamivudine, 100 vs. Lamivudine, 100 | 48/48 | HBeAg Seroconversion | Baseline HBV DNA levels ≤9.07 (log copies/ml) | 0.84 (0.47; 1.48) | -0.01 (-0.06; 0.03) | -69
Baseline HBV DNA levels >9.07–10.26 (log copies/ml) | 1.91 (1.16; 3.15) | 0.07 (0.02; 0.12) | 14
Lau, 2005^56^ Peginterferon alfa-2a, 26 + Lamivudine, 100 vs. peginterferon alfa-2a, 26 | 48/48 | HBeAg Seroconversion | Baseline HBV DNA levels>10.26 (log copies/ml) | 1.27 (0.59; 2.75) | 0.01 (-0.02; 0.05) | 90
Lau, 2005^56^ Peginterferon alfa-2a, 26 + Lamivudine, 100 vs. peginterferon alfa-2a, 26 | 48/48 | HBeAg Seroconversion | Baseline HBV DNA levels ≤9.07 (log copies/ml) | 0.54 (0.32; 0.91) | -0.06 (-0.11; -0.01) | -16
Baseline HBV DNA levels >9.07–10.26 (log copies/ml) | 1.03 (0.68; 1.54) | 0.00 (-0.06; 0.06) | 271
Bonino, 2007^114^ Peginterferon alfa-2a, 26 + Placebo, vs. Lamivudine, 100 | 48/48 | Sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | Baseline HBV DNA >8.42 log 10 copies/ml | 1.80 (0.91; 3.57) | 0.18 (-0.02; 0.37) | 6
Bonino, 2007^114^ Peginterferon alfa-2a, 26 + Placebo, vs. Lamivudine, 100 | 48/48 | Sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | Baseline HBV DNA >6.12–8.42 log 10 copies/ml | 3.87 (2.55; 5.88) | 0.61 (0.46; 0.76) | 2
Baseline HBV DNA <6.12 log 10 copies/ml | 1.27 (0.71; 2.30) | 0.08 (-0.11; 0.26) | 13
Lau, 2005^56^ Peginterferon alfa-2a, 26 + Placebo,. vs. Lamivudine, 100 | 48/48 | HBeAg Seroconversion | Baseline HBV DNA levels >10.26 (log copies/ml) | 1.58 (0.62; 4.01) | 0.01 (-0.02; 0.04) | 67
Lau, 2005^56^ Peginterferon alfa-2a, 26 + Placebo,. vs. Lamivudine, 100 | 48/48 | HBeAg Seroconversion | Baseline HBV DNA levels ≤9.07 (log copies/ml) | 1.55 (0.95; 2.51) | 0.05 (0.00; 0.10) | 21
Baseline HBV DNA levels >9.07–10.26 (log copies/ml) | 1.86 (1.13; 3.08) | 0.07 (0.01; 0.12) | 15
Zhao, 2007^81^ Peginterferon alfa-2b, 11 vs. Interferon Alfa 2b, 1 | 24/24 | Multivariate adjusted odds ratio of sustained combined response: HBeAg negative, HBV DNA <5 log 10 copies/mL, and normal ALT level | Baseline HBV DNA >8.1 vs. < 8.1 log 10 copies/mL | 0.53 (0.22; 1.28)
Chan, 2006^118^ Peginterferon alfa-2b, 14 + Lamivudine, 100 vs. Lamivudine, 100 | 60/52 | Adjusted for treatment allocation, HBV genotype, baseline ALT odds ratio of persistent HBeAg loss | Log HBV DNA at baseline (copies/mL) | 0.70 (0.38; 1.30)
Adjusted for treatment allocation, HBV DNA genotype, IL-1b-511 polymorphism, baseline ALT odds ratio of persistent HBeAg loss | Log HBV DNA at baseline (copies/mL) | 0.65 (0.35; 1.20)
Janssen, 2005^78^ Peginterferon alfa-2b, 14 + Lamivudine, 100 vs. Peginterferon alfa-2b, 14 | 52/52 | Adjusted odds ratio of sustained HBeAg loss | Low baseline viral load | 1.60 (1.30; 1.80)
ALT normalization
van Zonneveld, 2006^125^ Peginterferon alfa-2b, 14 +Lamivudine, 100 vs. Peginterferon alfa-2b, 14 | 52/52 | Improved inflammatory changes in the liver as decrease of at least 2 points for the necroinflammatory score (range 0–18) | No ALT normalization | 0.61 (0.28; 1.36) | -0.04 (-0.10; 0.02) | -27
Improved fibrosis scores as decrease of at least 1 point for the fibrosis score (range 0–6) | No ALT normalization | 0.87 (0.30; 2.54) | -0.01 (-0.05; 0.04) | -176
Change in weight
Bonino, 2007^114^ Peginterferon alfa-2a, 26 vs. Lamivudine, 100 | 48/48 | Adjusted odds ratios of sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | Weight (10 kg increase) | 1.03 (0.81; 1.30)
Body weight: 10 kg increase | 1.00 (1.00; 1.00)
Duration of hepatitis
Barbaro, 2001^66^ Interferon Alfa 2b, 4 + Lamivudine, 100 vs. Lamivudine, 100 | 24/52 | Odds Ratio of sustained virologic response (sustained suppression of serum levels of HBeAg and HBV DNA) in those with an estimated duration of disease of 10 years or less independent on gender and age | Duration of disease | 2.55 (1.26; 5.19)
HBeAg negative
Chang, 2005^76^ Entecavir, 0.10 vs. Lamivudine, 100 | 48/48 | Undetectable HBV DNA level by bDNA assay and normal ALT level | HBeAg negative | 10.11 (0.62; 164.68) | 0.35 (0.11; 0.60) | 3
Chang, 2005^76^ Entecavir, 0.50 vs. Entecavir, 0.10 | 48/48 | Undetectable HBV DNA level by bDNA assay and normal ALT level | HBeAg negative | 1.13 (0.46; 2.77) | 0.05 (-0.29; 0.38) | 21
Chang, 2005^76^ Entecavir, 0.50 vs. Lamivudine, 100 | 48/48 | Undetectable HBV DNA level by bDNA assay and normal ALT level | HBeAg negative | 11.38 (0.70; 184.38) | 0.40 (0.14; 0.66) | 2
Chang, 2005^76^ Entecavir, 1 vs. Entecavir, 0.10 | 48/48 | Undetectable HBV DNA level by bDNA assay and normal ALT level | HBeAg negative | 1.89 (0.90; 3.94) | 0.31 (-0.02; 0.64) | 3
Chang, 2005^76^ Entecavir, 1 vs. Entecavir, 0.50 | 48/48 | Undetectable HBV DNA level by bDNA assay and normal ALT level | HBeAg negative | 1.67 (0.81; 3.41) | 0.27 (-0.08; 0.61) | 4
Chang, 2005^76^ Entecavir, 1 vs. Lamivudine, 100 | 48/48 | Undetectable HBV DNA level by bDNA assay and normal ALT level | HBeAg negative | 18.38 (1.18; 285.96) | 0.67 (0.41; 0.92) | 1
Liaw, 2004^51^ Lamivudine, 100 vs. Placebo | 130/130 | Overall disease progression by the first occurrence of any of the following: an increase of at least 2 points in the Child-Pugh score | HBeAg negative | 0.72 (0.36; 1.43) | -0.02 (-0.05; 0.02) | -59
Chan, 2005^117^ Peginterferon alfa-2b, 14 + Lamivudine, 100 vs. Lamivudine, 100 | 60/52 | Biochemical relapse as ALT elevation to >2 times upper limit of laboratory normal | Negative HBeAg at week 53 | 2.14 (0.96; 4.80) | 0.16 (0.00; 0.32) | 6
Lai, 2007^71^ Telbivudine, 600 vs. Lamivudine, 100 | 52/52 | ALT normalization | HBeAg-negative patients | 0.94 (0.84; 1.04) | -0.05 (-0.13; 0.03) | -19
Lai, 2007^71^ Telbivudine, 600 vs. Lamivudine, 100 | 52/52 | Primary treatment failure -serum HBV DNA levels remained above 5 log10 copies per milliliter | HBeAg-negative patients | 0.17 (0.02; 1.39) | -0.02 (-0.05; 0.00) | -45
Lai, 2007^71^ Telbivudine, 600 vs. Lamivudine, 100 | 52/52 | Reduction of at least two points in the Knodell necroinflammatory score, with no worsening in the Knodell fibrosis score | HBeAg-negative patients | 1.01 (0.88; 1.15) | 0.01 (-0.08; 0.09) | 168
Lai, 2007^71^ Telbivudine, 600 vs. Lamivudine, 100 | 52/52 | Ishak fibrosis scores improved | HBeAg-negative patients | 1.28 (1.07; 1.54) | 0.13 (0.04; 0.22) | 8
Lai, 2007^71^ Telbivudine, 600 vs. Lamivudine, 100 | 52/52 | Serum HBV DNA undetectable by PCR | HBeAg-negative patients | 1.24 (1.12; 1.36) | 0.17 (0.10; 0.24) | 6
Lai, 2007^71^ Telbivudine, 600 vs. Lamivudine, 100 | Serum HBV DNA undetectable by PCR | HBeAg-negative patients | 1.30 (1.15; 1.48) | 0.18 (0.10; 0.27) | 6
Lai, 2007^71^ Telbivudine, 600 vs. Lamivudine, 100 | | HBV DNA <3 log10 copies/ml | HBeAg-negative patients | 0.91 (0.49; 1.67) | -0.01 (-0.06; 0.04) | -122
Lai, 2007^71^ Telbivudine, 600 vs. Lamivudine, 100 | | Reduction in serum HBV DNA levels to <5 log 10 copies per milliliter with HBeAg loss, or normalization of ALT | HBeAg-negative patients | 0.97 (0.88; 1.08) | -0.02 (-0.10; 0.06) | -50
Lai, 2007^71^ Telbivudine, 600 vs. Lamivudine, 100 | | HBV DNA <3–4 log10 copies/ml | HBeAg-negative patients | 0.65 (0.35; 1.18) | -0.04 (-0.09; 0.01) | -25
Lai, 2007^71^ Telbivudine, 600 vs. Lamivudine, 100 | | Viral breakthrough - at least two consecutive determinations of an increase in HBV DNA by at least 1 log 10 copy per milliliter from nadir | HBeAg-negative patients | 0.18 (0.07; 0.46) | -0.10 (-0.15; -0.05) | -10
Lai, 2007^71^ Telbivudine, 600 vs. Lamivudine, 100 | | Viral breakthrough - at least two consecutive determinations of an increase in HBV DNA by at least 1 log 10 copy per milliliter from nadir with treatment-emergent resistance mutations | HBeAg-negative patients | 0.21 (0.08; 0.54) | -0.08 (-0.13; -0.04) | -12
HBV DNA >4 log10copies/ml | HBeAg-negative patients | 0.55 (0.27; 1.13) | -0.04 (-0.09; 0.01) | -25
HBeAg positive
Chang, 2005^76^ Entecavir, 0.10 vs. Lamivudine, 100 | 48/48 | Undetectable HBV DNA level by bDNA assay, normal ALT level, and loss of HBeAg if HBeAg positive at baseline | HBeAg positive | 0.21 (0.01; 4.26) | -0.06 (-0.16; 0.04) | -16
Chang, 2005^76^ Entecavir, 0.10 vs. Lamivudine, 100 | 48/48 | HBeAg loss | HBeAg positive | 0.15 (0.01; 2.83) | -0.09 (-0.21; 0.02) | -11
HBeAg seroconversion | HBeAg positive | 0.21 (0.01; 4.26) | -0.06 (-0.16; 0.04) | -16
Chang, 2005^76^ Entecavir, 0.50 vs. Entecavir, 0.10 Entecavir, 0.50 vs. Lamivudine, 100 | 48/48 | Undetectable HBV DNA level by bDNA assay, normal ALT level, and loss of HBeAg if HBeAg positive at baseline | HBeAg positive | 6.58 (0.35; 122.21) | 0.09 (-0.02; 0.21) | 11
Chang, 2005^76^ Entecavir, 0.50 vs. Entecavir, 0.10 Entecavir, 0.50 vs. Lamivudine, 100 | 48/48 | HBeAg loss | HBeAg positive | 6.58 (0.35; 122.21) | 0.09 (-0.02; 0.21) | 11
Chang, 2005^76^ Entecavir, 0.50 vs. Entecavir, 0.10 Entecavir, 0.50 vs. Lamivudine, 100 | 48/48 | HBeAg seroconversion | HBeAg positive | 2.82 (0.12; 66.62) | 0.03 (-0.05; 0.12) | 32
Chang, 2005^76^ Entecavir, 0.50 vs. Entecavir, 0.10 Entecavir, 0.50 vs. Lamivudine, 100 | 48/48 | Undetectable HBV DNA level by bDNA assay, normal ALT level, and loss of HBeAg if HBeAg positive at baseline | HBeAg positive | 1.50 (0.27; 8.38) | 0.03 (-0.10; 0.16) | 32
Chang, 2005^76^ Entecavir, 0.50 vs. Entecavir, 0.10 Entecavir, 0.50 vs. Lamivudine, 100 | 48/48 | HBeAg loss | HBeAg positive | 1.00 (0.22; 4.59) | 0.00 (-0.14; 0.14)
HBeAg seroconversion | HBeAg positive | 0.50 (0.05; 5.24) | -0.03 (-0.13; 0.07) | -32
Chang, 2005^76^ Entecavir, 1 vs. Entecavir, 0.10 | 48/48 | Undetectable HBV DNA level by bDNA assay, normal ALT level, and loss of HBeAg if HBeAg positive at baseline | HBeAg positive | 5.54 (0.28; 110.42) | 0.07 (-0.04; 0.19) | 13
Chang, 2005^76^ Entecavir, 1 vs. Entecavir, 0.10 | 48/48 | HBeAg loss | HBeAg positive | 7.75 (0.42; 143.52) | 0.11 (-0.02; 0.24) | 9
HBeAg seroconversion | HBeAg positive | 3.32 (0.14; 78.25) | 0.04 (-0.06; 0.13) | 27
Chang, 2005^76^ Entecavir, 1 vs. Entecavir, 0.50 | 48/48 | Undetectable HBV DNA level by bDNA assay, normal ALT level, and loss of HBeAg if HBeAg positive at baseline | HBeAg positive | 0.79 (0.14; 4.39) | -0.02 (-0.16; 0.12) | -51
Chang, 2005^76^ Entecavir, 1 vs. Entecavir, 0.50 | 48/48 | HBeAg loss | HBeAg positive | 1.19 (0.26; 5.40) | 0.02 (-0.14; 0.17) | 58
HBeAg seroconversion | HBeAg positive | 1.19 (0.08; 18.06) | 0.01 (-0.09; 0.10) | 173
Chang, 2005^76^ Entecavir, 1 vs. Lamivudine, 100 | 48/48 | Undetectable HBV DNA level by bDNA assay, normal ALT level, and loss of HBeAg if HBeAg positive at baseline | HBeAg positive | 1.19 (0.18; 7.86) | 0.01 (-0.12; 0.14) | 86
Chang, 2005^76^ Entecavir, 1 vs. Lamivudine, 100 | 48/48 | HBeAg loss | HBeAg positive | 1.19 (0.26; 5.40) | 0.02 (-0.14; 0.17) | 58
HBeAg seroconversion | HBeAg positive | 0.59 (0.06; 6.18) | -0.03 (-0.14; 0.08) | -39
Kim, 2006^54^ Lamivudine, 100 vs. Placebo | 80/80 | Odds ratio of hepatic decompensation change in the Child-Turcotte-Pugh score of 2 or more points adjusted for treatments, ALT, HBV DNA, sex, YMDD variant, platelet, bilirubin, albumin | HBeAg positive status | 1.00 (1.00; 1.00)
Liaw, 2004^51^ Lamivudine, 100 vs. Placebo | 130/130 | Overall disease progression | HBeAg positive | 0.30 (0.16; 0.55) | -0.08 (-0.13; -0.04) | -12
Cindoruk, 2007^115^ Peginterferon alfa-2a, 26 + Lamivudine, 100 vs. Lamivudine, 100 | 9/9 | Adjusted for treatment status odds ratio of sustained response: HBeAg seroconversion, HBV DNA disappearance and ALT normalization in HBeAg (+) patients. In HBeAg (-) patients: loss of HBV DNA, ALT normalization | Baseline HBeAg status | 4.72 (2.66; 8.38)
Chan, 2005^117^ Peginterferon alfa-2b, 14 + Lamivudine, 100 vs. Lamivudine, 100 | 60/52 | Biochemical relapse as ALT elevation to >2 times upper limit of laboratory normal | Positive HBeAg at week 52 | 0.55 (0.35; 0.85) | -0.28 (-0.47; -0.09) | -4
Lai, 2007^71^ Telbivudine, 600 vs. Lamivudine, 100 | 52/52 | ALT normalization | HBeAg-positive patients | 1.03 (0.96; 1.11) | 0.02 (-0.03; 0.08) | 43
Lai, 2007^71^ Telbivudine, 600 vs. Lamivudine, 100 | 52/52 | Primary treatment failure serum HBV DNA levels remained above 5 log10 copies per milliliter | HBeAg-positive patients | 0.36 (0.22; 0.57) | -0.09 (-0.12; -0.05) | -12
Lai, 2007^71^ Telbivudine, 600 vs. Lamivudine, 100 | 52/52 | Reduction of at least two points in the Knodell necroinflammatory score, with no worsening in the Knodell fibrosis score | HBeAg-positive patients | 1.15 (1.03; 1.27) | 0.08 (0.02; 0.15) | 12
Lai, 2007^71^ Telbivudine, 600 vs. Lamivudine, 100 | 52/52 | Ishak fibrosis scores improved | HBeAg-positive Patients | 1.11 (1.01; 1.23) | 0.07 (0.01; 0.13) | 14
Lai, 2007^71^ Telbivudine, 600 vs. Lamivudine, 100 | 52/52 | HBV DNA level below 5 log10 copies per milliliter and HBeAg loss | HBeAg-positive patients | 1.13 (0.90; 1.41) | 0.03 (-0.03; 0.08) | 35
Lai, 2007^71^ Telbivudine, 600 vs. Lamivudine, 100 | 52/52 | HBeAg loss | HBeAg-positive patients | 1.10 (0.88; 1.39) | 0.02 (-0.03; 0.08) | 41
Lai, 2007^71^ Telbivudine, 600 vs. Lamivudine, 100 | 52/52 | HBeAg seroconversion | HBeAg-positive patients | 1.04 (0.82; 1.33) | 0.01 (-0.04; 0.06) | 112
Lai, 2007^71^ Telbivudine, 600 vs. Lamivudine, 100 | 52/52 | Serum HBV DNA undetectable by PCR | HBeAg-positive patients | 1.49 (1.30; 1.70) | 0.20 (0.13; 0.26) | 5
Lai, 2007^71^ Telbivudine, 600 vs. Lamivudine, 100 | 52/52 | Serum HBV DNA undetectable by PCR | HBeAg-positive patients | 1.54 (1.27; 0.87) | 0.14 (0.08; 0.20) | 7
Lai, 2007^71^ Telbivudine, 600 vs. Lamivudine, 100 | 52/52 | HBV DNA <3 log10 copies/ml | HBeAg-positive patients | 0.93 (0.67; 1.29) | -0.01 (-0.05; 0.03) | -107
Lai, 2007^71^ Telbivudine, 600 vs. Lamivudine, 100 | 52/52 | Reduction in serum HBV DNA levels to < 5 log10 copies per milliliter with loss of hepatitis B e antigen, or normalization of ALT | HBeAg-positive patients | 1.13 (1.04; 1.22) | 0.08 (0.03; 0.14) | 12
Lai, 2007^71^ Telbivudine, 600 vs. Lamivudine, 100 | 52/52 | HBV DNA <3–4 log10 copies/ml | HBeAg-positive patients | 1.05 (0.79; 1.39) | 0.01 (-0.04; 0.06) | 119
Lai, 2007^71^ Telbivudine, 600 vs. Lamivudine, 100 | 52/52 | Viral breakthrough - at least two consecutive determinations of an increase in HBV DNA by at least 1 log10 copy per milliliter from nadir | HBeAg-positive patients | 0.38 (0.25; 0.59) | -0.09 (-0.13; -0.06) | -11
Lai, 2007^71^ Telbivudine, 600 vs. Lamivudine, 100 | 52/52 | Viral breakthrough - at least two consecutive determinations of an increase in HBV DNA by at least 1 log10 copy per milliliter from nadir with treatment-emergent resistance mutations | HBeAg-positive patients | 0.46 (0.28; 0.73) | -0.06 (-0.09; -0.03) | -17
HBV DNA >4 log10copies/ml | HBeAg-positive patients | 0.67 (0.54; 0.82) | -0.12 (-0.18; -0.06) | -8
Flink, 2005^120^ Peginterferon alfa-2b, 14+Lamivudine, 100 vs. Peginterferon alfa-2b, 14 | 52/52 | Adjusted relative risk of HBeAg loss | Host induced flares followed by a decline of 1 log HBV DNA or more within the 4 months vs. no flares | 2.40 (1.00; 5.80)
Gender
Jang, 2004^65^ Interferon Alfa 2b, 2 + Lamivudine, 100 vs. Lamivudine, 100 | 176/174 | Viral breakthrough as the reappearance of serum HBV-DNA by solution hybridization assay in at least two consecutive tests during lamivudine therapy following the disappearance of the serum HBV DNA | Sex | 1.00 (1.00; 1.00)
Kim, 2006^54^ Lamivudine, 100 vs. Placebo | 80/80 | Odds ratio of hepatic decompensation change in the Child-Turcotte-Pugh score of 2 or more points adjusted for treatments, ALT, HBV DNA, sex, YMDD variant, platelet, bilirubin, albumin | Sex | 1.00 (1.00; 1.00)
Liaw, 2004^51^ Lamivudine, 100 vs. Placebo | 130/130 | Overall disease progression | Male | 0.53 (0.33; 0.84) | -0.07 (-0.12; -0.01) | -15
Female | 0.12 (0.03; 0.58) | -0.03 (-0.06; -0.01) | -31
Bonino, 2007^114^ Peginterferon alfa-2a, 26 vs. Lamivudine, 100 | 48/48 | Adjusted odds ratios of sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | Female | 1.93 (1.1; 3.4)
Male | 0.68 (0.34; 1.37)
Bonino, 2007^114^ Peginterferon alfa-2a, 26 + Lamivudine, 100 vs. Lamivudine, 100 | 48/48 | Sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | Female | 1.46 (0.74; 2.89) | 0.15 (-0.10; 0.40) | 7
Male | 1.65 (1.15; 2.39) | 0.14 (0.04; 0.24) | 7
Bonino, 2007^114^ Peginterferon alfa-2a, 26 + Placebo vs. Lamivudine, 100 | 48/48 | Sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | Female | 1.20 (0.57; 2.55) | 0.06 (-0.20; 0.33) | 15
Male | 1.61 (1.11; 2.33) | 0.13 (0.03; 0.23) | 8
Zhao, 2007^81^ Peginterferon alfa-2b, 11 vs. Interferon Alfa 2b, 1 | 24/24 | Multivariate adjusted odds ratio of sustained combined response: HBeAg negative, HBV DNA <5 log10 copies/mL, and normal ALT level | Female | 0.59 (0.22;1.60)
Genotype
Wai, 2002^102^ Interferon Alfa 2b, 4 + Prednisone, 15 vs. Placebo for 6 weeks + 2 weeks rest then Interferon Alfa 2b, 4 | 24/24 | Adjusted for age, gender, baseline ALT, HBV DNA, and histology, precore G1896A mutation, core promoter A1762T, G1764A, and treatment with Interferon with and without prednisone pretreatment odds ratios of antiviral response: as sustained clearance of serum HBV DNA | HBV genotype B vs. C in patients with elevated baseline ALT | 1.47 (1.18; 1.82)
HBV genotype B vs. C | 1.28 (1.06; 1.42)
Bonino, 2007^114^ Peginterferon alfa-2a, 26 vs. Lamivudine, 100 | 48/48 | Adjusted odds ratios of sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | Genotype C vs. D | 3.30 (1.70; 6.50)
Bonino, 2007^114^ Peginterferon alfa-2a, 26 vs. Lamivudine, 100 | 48/48 | Adjusted odds ratios of sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | HBV genotype: A vs. D | 0.97 0.30; 2.70)
Bonino, 2007^114^ Peginterferon alfa-2a, 26 vs. Lamivudine, 100 | 48/48 | Adjusted odds ratios of sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | HBV genotype C vs. D | 2.90 (1.70; 5.00)
Bonino, 2007^114^ Peginterferon alfa-2a, 26 vs. Lamivudine, 100 | 48/48 | Adjusted odds ratios of sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | HBV genotype: A vs. C | 0.33 (0.10; 0.90)
Bonino, 2007^114^ Peginterferon alfa-2a, 26 vs. Lamivudine, 100 | 48/48 | Adjusted odds ratios of sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | HBV genotype: A vs. B | 0.42 (0.10; 1.20)
Bonino, 2007^114^ Peginterferon alfa-2a, 26 vs. Lamivudine, 100 | 48/48 | Adjusted odds ratios of sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | HBV genotype: B vs. D | 2.31 (1.30; 4.20)
Bonino, 2007^114^ Peginterferon alfa-2a, 26 vs. Lamivudine, 100 | 48/48 | Adjusted odds ratios of sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | HBV genotype: B vs. C | 0.79 (0.50; 1.30)
Bonino, 2007^114^ Peginterferon alfa-2a, 26 vs. Lamivudine, 100 | 48/48 | Adjusted odds ratios of sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | Genotype (C vs. D) 1 year of followup | 5.46 (2.46; 12.10)
Bonino, 2007^114^ Peginterferon alfa-2a, 26 vs. Lamivudine, 100 | 48/48 | Adjusted odds ratios of sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | Genotype (B vs. D) | 3.69 (1.54; 8.79)
Genotype (A vs. D) | 2.58 (0.73; 9.20)
Bonino, 2007^114^ Peginterferon alfa-2a, 26+Lamivudine, 100 vs. Lamivudine, 100 | 48/48 | Sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | Genotype B | 0.57 (0.29; 1.11) | -0.17 (-0.35; 0.02) | -6
Bonino, 2007^114^ Peginterferon alfa-2a, 26+Lamivudine, 100 vs. Lamivudine, 100 | 48/48 | Sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | Genotype D | 3.33 (1.53; 7.27) | 0.26 (0.11; 0.41) | 4
Bonino, 2007^114^ Peginterferon alfa-2a, 26+Lamivudine, 100 vs. Lamivudine, 100 | 48/48 | Sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | Genotype C | 2.09 (1.29; 3.40) | 0.29 (0.12; 0.45) | 3
Genotype A | 1.60 (0.17; 14.63) | 0.08 (-0.26; 0.41) | 13
Lau, 2005^56^ Peginterferon alfa-2a, 26 + Lamivudine, 100 vs. Lamivudine, 100 | 48/48 | HBeAg Seroconversion | HBV genotype D | 0.67 (0.11; 3.97) | 0.00 (-0.02; 0.01) | -274
Lau, 2005^56^ Peginterferon alfa-2a, 26 + Lamivudine, 100 vs. Lamivudine, 100 | 48/48 | HBeAg Seroconversion | HBV genotype C | 1.49 (0.96; 2.31) | 0.05 (0.00; 0.11) | 19
Lau, 2005^56^ Peginterferon alfa-2a, 26 + Lamivudine, 100 vs. Lamivudine, 100 | 48/48 | HBeAg Seroconversion | HBV genotype B | 1.42 (0.78; 2.58) | 0.03 (-0.02; 0.07) | 38
HBV genotype A | 1.34 (0.30; 5.92) | 0.00 (-0.02; 0.02) | 268
Lau, 2005^56^ Peginterferon alfa-2a, 26 + Lamivudine, 100 vs. peginterferon alfa-2a, 26 | 48/48 | HBeAg Seroconversion | HBV genotype D | 1.00 (0.14; 7.05) | 0.00 (-0.01; 0.01)
Lau, 2005^56^ Peginterferon alfa-2a, 26 + Lamivudine, 100 vs. peginterferon alfa-2a, 26 | 48/48 | HBeAg Seroconversion | HBV genotype C | 0.86 (0.59; 1.25) | -0.03 (-0.09; 0.04) | -39
Lau, 2005^56^ Peginterferon alfa-2a, 26 + Lamivudine, 100 vs. peginterferon alfa-2a, 26 | 48/48 | HBeAg Seroconversion | HBV genotype B | 1.04 (0.60; 1.80) | 0.00 (-0.04; 0.05) | 271
HBV genotype A | 0.33 (0.11; 1.02) | -0.03 (-0.06; 0.00) | -34
Bonino, 2007^114^ Peginterferon alfa-2a, 26 + Placebo, vs. Lamivudine, 100 | 48/48 | Sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | Genotype D | 1.47 (0.59; 3.69) | 0.05 (-0.07; 0.18) | 19
Bonino, 2007^114^ Peginterferon alfa-2a, 26 + Placebo, vs. Lamivudine, 100 | 48/48 | Sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | Genotype C | 2.22 (1.36; 3.63) | 0.32 (0.15; 0.50) | 3
Bonino, 2007^114^ Peginterferon alfa-2a, 26 + Placebo, vs. Lamivudine, 100 | 48/48 | Sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | Genotype B | 1.14 (0.70; 1.85) | 0.05 (-0.15; 0.26) | 18
Genotype A | 2.18 (0.27; 17.32) | 0.15 (-0.20; 0.50) | 7
Lau, 2005^56^ Peginterferon alfa-2a, 26 + Placebo vs. Lamivudine, 100 | 48/48 | HBeAg Seroconversion | HBV genotype D | 0.67 (0.11; 3.97) | 0.00 (-0.02; 0.01) | -274
Lau, 2005^56^ Peginterferon alfa-2a, 26 + Placebo vs. Lamivudine, 100 | 48/48 | HBeAg Seroconversion | HBV genotype C | 1.73 (1.13; 2.65) | 0.08 (0.02; 0.14) | 13
Lau, 2005^56^ Peginterferon alfa-2a, 26 + Placebo vs. Lamivudine, 100 | 48/48 | HBeAg Seroconversion | HBV genotype B | 1.36 (0.74; 2.48) | 0.02 (-0.02; 0.07) | 45
HBV genotype A | 4.01 (1.15; 14.07) | 0.03 (0.01; 0.06) | 30
Zhao, 2007^81^ Peginterferon alfa-2b, 11 vs. Interferon Alfa 2b, 1 | 24/24 | Multivariate adjusted odds ratio of sustained combined response: HBeAg negative, HBV DNA <5 log10 copies/mL, and normal ALT level | Genotype C vs. B | 0.19 (0.08; 0.46)
Chan, 2006^118^ Peginterferon alfa-2b, 14 +Lamivudine, 100 vs. Lamivudine, 100 | 60/52 | Adjusted for treatment allocation, hepatitis B virus (HBV) genotype, baseline Alanine aminotransferase and log HBV DNA odds ratio of persistent HBeAg loss | interleukin (IL)-1b-511 baseline genotype T/T vs. C/C | 4.10 (0.31; 55.90)
Chan, 2006^118^ Peginterferon alfa-2b, 14 +Lamivudine, 100 vs. Lamivudine, 100 | 60/52 | Adjusted for treatment allocation, hepatitis B virus (HBV) genotype, baseline Alanine aminotransferase and log HBV DNA odds ratio of persistent HBeAg loss | Interleukin (IL)-1b-511 baseline genotype C/T vs. C/C | 10.37 (1.11; 96.96)
Chan, 2006^118^ Peginterferon alfa-2b, 14 +Lamivudine, 100 vs. Lamivudine, 100 | 60/52 | Adjusted for treatment allocation, hepatitis B virus (HBV) genotype, baseline Alanine aminotransferase and log HBV DNA odds ratio of persistent HBeAg loss | interleukin (IL)-1b-511 baseline genotype C/T and T/T vs. C/C | 8.30 (0.93; 73.50)
Chan, 2006^118^ Peginterferon alfa-2b, 14 +Lamivudine, 100 vs. Lamivudine, 100 | 60/52 | Adjusted for treatment allocation, hepatitis B virus (HBV) genotype, baseline Alanine aminotransferase and log HBV DNA odds ratio of persistent HBeAg loss | interleukin (IL)-1b-31 baseline genotype C/T vs. T/T | 7.90 00.85; 73.60)
Chan, 2006^118^ Peginterferon alfa-2b, 14 +Lamivudine, 100 vs. Lamivudine, 100 | 60/52 | Adjusted for treatment allocation, hepatitis B virus (HBV) genotype, baseline Alanine aminotransferase and log HBV DNA odds ratio of persistent HBeAg loss | interleukin (IL)-1b-31 baseline genotype C/T and C/C vs. T/T | 7.97 (0.90; 70.95)
Chan, 2006^118^ Peginterferon alfa-2b, 14 +Lamivudine, 100 vs. Lamivudine, 100 | 60/52 | Adjusted for treatment allocation, hepatitis B virus (HBV) genotype, baseline Alanine aminotransferase and log HBV DNA odds ratio of persistent HBeAg loss | interleukin (IL)-1b-31 baseline genotype C/C vs. T/T | 8.10 (0.73; 90.80)
Chan, 2006^118^ Peginterferon alfa-2b, 14 +Lamivudine, 100 vs. Lamivudine, 100 | 60/52 | Adjusted for treatment allocation, hepatitis B virus (HBV) genotype, baseline Alanine aminotransferase and log HBV DNA odds ratio of persistent HBeAg loss | IL-1 receptor antagonist genotype IL-1RN 1/2 vs. 1/1 | 0.82 (0.14; 5.10)
Chan, 2006^118^ Peginterferon alfa-2b, 14 +Lamivudine, 100 vs. Lamivudine, 100 | 60/52 | Adjusted for treatment allocation, hepatitis B virus (HBV) genotype, baseline Alanine aminotransferase and log HBV DNA odds ratio of persistent HBeAg loss | Haplotype -511/-31 of interleukin (IL)-1b C-T vs. T-C | 0.53 (0.22; 1.30)
Chan, 2006^118^ Peginterferon alfa-2b, 14 +Lamivudine, 100 vs. Lamivudine, 100 | 60/52 | Adjusted for treatment allocation, hepatitis B virus (HBV) genotype, baseline Alanine aminotransferase and log HBV DNA odds ratio of persistent HBeAg loss | Haplotype -511/-31 of interleukin (IL)-1b C-C vs. T-C | 6.90 (0.49; 98.10)
Chan, 2006^118^ Peginterferon alfa-2b, 14 +Lamivudine, 100 vs. Lamivudine, 100 | 60/52 | Adjusted for treatment allocation, hepatitis B virus (HBV) genotype, baseline Alanine aminotransferase and log HBV DNA odds ratio of persistent HBeAg loss | Genotype HBV DNA C (vs. B) | 2.10 (0.48; 8.60)
Genotype HBV DNA C (vs. B) | 1.80 (0.44; 7.40)
Janssen, 2005^78^ Peginterferon alfa-2b, 14 + Lamivudine, 100 vs. Peginterferon alfa-2b, 14 | 52/52 | Adjusted odds ratio of sustained HBeAg loss | HBV genotype B vs. C | 2.20 (0.70; 7.00)
Buster, 2007^124^ Peginterferon alfa-2b, 14 + Lamivudine, 100 vs. Peginterferon alfa-2b, 14 | 52/52 | Adjusted relative risk of HBeAg seroconversion and HBV DNA <10,000 copies/ml. | HBV genotype and high baseline necroinflammatory score | 1.31 (1.05; 1.65)
Janssen, 2005^78^ Peginterferon alfa-2b, 14 + Lamivudine, 100 vs. Peginterferon alfa-2b, 14 | 52/52 | Adjusted odds ratio of Sustained HBeAg loss | HBV genotype A vs. D | 2.40 (1.30; 4.60)
HBV genotype A vs. C | 3.60 (1.40; 8.90)
Buster, 2007^124^ Peginterferon alfa-2b, 14 + Lamivudine, 100 vs. Peginterferon alfa-2b, 14 | 52/52 | Adjusted relative risk of HBeAg seroconversion and HBV DNA <10,000 copies/ml | Genotype B vs. D | 4.59 (1.14; 18.43)
Buster, 2007^124^ Peginterferon alfa-2b, 14 + Lamivudine, 100 vs. Peginterferon alfa-2b, 14 | 52/52 | Adjusted relative risk of HBeAg seroconversion and HBV DNA <10,000 copies/ml | Genotype B vs. C | 12.13 (1.24; 118.30)
Buster, 2007^124^ Peginterferon alfa-2b, 14 + Lamivudine, 100 vs. Peginterferon alfa-2b, 14 | 52/52 | Adjusted relative risk of HBeAg seroconversion and HBV DNA <10,000 copies/ml | Genotype A vs. D | 4.28 (1.39; 13.21)
Genotype A vs. C | 11.30 (1.38; 92.57)
Westland, 2003^126^ Adefovir dipivoxil, 10 vs. Lamivudine, 100 | 48/0 | Relative risk of viral response (reduction in HBV DNA) adjusted for baseline serum HBV DNA and ALT levels among different viral genotypes | Genotype
Mutation
Barbaro, 2001^66^ Interferon Alfa 2b, 4 + Lamivudine, 100 vs. Lamivudine, 100 | 24/52 | Odds ratio of sustained virologic response (sustained suppression of serum levels of HBeAg and HBV DNA) in those with the absence of YMDD mutation independent on gender and age | No YMDD mutation | 2.73 (1.09; 7.42)
Kim, 2006^54^ Lamivudine, 100 vs. Placebo | 80/80 | Odds ratio of hepatic decompensation change in the Child-Turcotte-Pugh score of 2 or more points adjusted for treatments, ALT, HBV DNA, sex, YMDD variant, platelet, bilirubin, albumin | YMDD | 1.00 (1.00; 1.00)
Dienstag, 2003^107^ Lamivudine, 100 vs. Lamivudine, 100 | 144/96 | Worsened scores | YMDD for 1–2 years | 1.50 (0.25; 8.85) | 0.01 (-0.02; 0.04) | 152
Dienstag, 2003^107^ Lamivudine, 100 vs. Lamivudine, 100 | 144/96 | Improved (decrease of 2 points) HAI necroinflammatory score | YMDD for 1–2 years | 1.33 (0.30; 5.86) | 0.01 (-0.03; 0.04) | 152
Dienstag, 2003^107^ Lamivudine, 100 vs. Lamivudine, 100 | 144/96 | No change | YMDD for 1–2 years | 0.60 (0.15; 2.47) | -0.01 (-0.05; 0.02) | -76
Dienstag, 2003^107^ Lamivudine, 100 vs. Lamivudine, 100 | 144/96 | Worsened scores | YMDD for >2 years | 5.00 (0.59; 42.29) | 0.03 (0.00; 0.06) | 38
Dienstag, 2003^107^ Lamivudine, 100 vs. Lamivudine, 100 | 144/96 | Improved (decrease of 2 points) HAI necroinflammatory score | YMDD for >2 years | 0.40 (0.13; 01.25) | -0.04 (-0.09; 0.01) | -25
Dienstag, 2003^107^ Lamivudine, 100 vs. Lamivudine, 100 | 144/96 | No change | YMDD for >2 years | 1.18 (0.55; 2.55) | 0.01 (-0.05; 0.07) | 76
Dienstag, 2003^107^ Lamivudine, 100 vs. Lamivudine, 100 | 144/96 | Worsened scores | YMDD for <1 years | 5.00 (0.24; 103.29) | 0.01 (-0.01; 0.04) | 76
Dienstag, 2003^107^ Lamivudine, 100 vs. Lamivudine, 100 | 144/96 | Improved (decrease of 2 points) HAI necroinflammatory score | YMDD for <1 years | 0.17 (0.02; 1.37) | -0.03 (-0.07; 0.00) | -30
No change | YMDD for <1 years | 2.00 (0.51; 7.85) | 0.02 (-0.02; 0.06) | 51
Yuen, 2005^111^ Lamivudine, 100 vs. Lamivudine, 100 | 48/48 | Change in necroinflammation: Worsening | YMDD | 1.09 (0.06; 19.21) | -0.05 (-0.23; 0.13) | -20
Yuen, 2005^111^ Lamivudine, 100 vs. Lamivudine, 100 | 48/48 | Change in fibrosis: Worsening | YMDD | 0.95 (0.14; 6.44) | -0.01 (-0.28; 0.27) | -140
Yuen, 2005^111^ Lamivudine, 100 vs. Lamivudine, 100 | 48/48 | Change in necroinflammation: Improvement | YMDD | 1.04 (0.53; 2.05) | 0.02 (-0.37; 0.41) | 47
Yuen, 2005^111^ Lamivudine, 100 vs. Lamivudine, 100 | 48/48 | Change in fibrosis: Improvement | YMDD | 2.54 (0.11; 57.25) | -0.02 (-0.19; 0.16) | -60
Yuen, 2005^111^ Lamivudine, 100 vs. Lamivudine, 100 | 48/48 | Change in necroinflammation: No change | YMDD | 1.07 (0.43; 2.66) | 0.03 (-0.36; 0.42) | 35
Change in fibrosis: No change | YMDD | 1.03 (0.74; 1.42) | 0.02 (-0.25; 0.30) | 42
Dienstag, 2003^107^ Lamivudine, 100 vs. Lamivudine, 100 | 144/96 | Worsened | No YMDD | 7.00 (0.36; 134.37) | 0.02 (-0.01; 0.05) | 51
Dienstag, 2003^107^ Lamivudine, 100 vs. Lamivudine, 100 | 144/96 | Improved (decrease of 2 points) HAI necroinflammatory score | No YMDD | 0.18 (0.05; 0.59) | -0.09 (-0.15; -0.04) | -11
No change | No YMDD | 3.20 (1.20; 8.52) | 0.07 (0.02; 0.13) | 14
Lau, 2005^56^ Peginterferon alfa-2a, 26+Lamivudine, 100 vs. Lamivudine, 100 | 48/48 | HBeAg Seroconversion | Previous treatment: LAM | 0.86 (0.29; 2.53) | 0.00 (-0.03; 0.02) | -278
Treatment status
Lau, 2005^56^ Peginterferon alfa-2a, 26 + Lamivudine, 100 vs. Lamivudine, 100 | 48/48 | HBeAg Seroconversion | Previous treatment: IFN | 2.76 (0.89; 8.56) | 0.03 (0.00; 0.05) | 39
Lau, 2005^56^ Peginterferon alfa-2a, 26 + Lamivudine, 100 vs. Lamivudine, 100 | 48/48 | HBeAg Seroconversion | No previous exposure to lamivudine | 1.52 (1.08; 2.12) | 0.09 (0.02; 0.15) | 12
No previous exposure to conventional interferon | 1.32 (0.94; 1.84) | 0.06 (-0.01; 0.12) | 18
Lau, 2005^56^ Peginterferon alfa-2a, 26 + Lamivudine, 100 vs. peginterferon alfa-2a, 26 | 48/48 | HBeAg Seroconversion | Previous treatment: LAM | 0.60 (0.22; 1.63) | -0.01 (-0.04; 0.01) | -68
Lau, 2005^56^ Peginterferon alfa-2a, 26 + Lamivudine, 100 vs. peginterferon alfa-2a, 26 | 48/48 | HBeAg Seroconversion | Previous treatment: IFN | 0.85 (0.39; 1.86) | -0.01 (-0.04; 0.03) | -135
Lau, 2005^56^ Peginterferon alfa-2a, 26 + Lamivudine, 100 vs. peginterferon alfa-2a, 26 | 48/48 | HBeAg Seroconversion | No previous exposure to lamivudine | 0.88 (0.67; 1.17) | -0.03 (-0.11; 0.04) | -30
No previous exposure to conventional interferon | 0.85 (0.64; 1.14) | -0.04 (-0.11; 0.03) | -25
Lau, 2005^56^ Peginterferon alfa-2a, 26 + Placebo vs. Lamivudine, 100 | 48/48 | HBeAg Seroconversion | Previous treatment: LAM | 1.43 (0.55; 3.71) | 0.01 (-0.02; 0.04) | 90
Lau, 2005^56^ Peginterferon alfa-2a, 26 + Placebo vs. Lamivudine, 100 | 48/48 | HBeAg Seroconversion | Previous treatment: IFN | 3.26 (1.08; 9.88) | 0.03 (0.00; 0.06) | 30
Lau, 2005^56^ Peginterferon alfa-2a, 26 + Placebo vs. Lamivudine, 100 | 48/48 | HBeAg Seroconversion | No previous exposure to lamivudine | 1.72 (1.24; 2.38) | 0.12 (0.05; 0.19) | 8
No previous exposure to conventional interferon | 1.55 (1.12; 2.14) | 0.10 (0.03; 0.17) | 10
Flink, 2006^121^ Peginterferon alfa-2b, 14 + Lamivudine, 100 vs. Peginterferon alfa-2b, 14 | 52/52 | ALT normalization | Previous treatment: LAM | 1.36 (0.31; 5.97) | 0.01 (-0.03; 0.04) | 144
Flink, 2006^121^ Peginterferon alfa-2b, 14 + Lamivudine, 100 vs. Peginterferon alfa-2b, 14 | 52/52 | ALT normalization | Previous treatment: IFN and LAM | 7.14 (0.37; 137.02) | 0.02 (-0.01; 0.05) | 51
Flink, 2006^121^ Peginterferon alfa-2b, 14 + Lamivudine, 100 vs. Peginterferon alfa-2b, 14 | 52/52 | ALT normalization | Previous treatment: IFN | 1.27 (0.35; 4.66) | 0.01 (-0.03; 0.04) | 141
Flink, 2006^121^ Peginterferon alfa-2b, 14 + Lamivudine, 100 vs. Peginterferon alfa-2b, 14 | 52/52 | Naive | 0.94 (0.62; 1.41) | -0.02 (-0.11; 0.08) | -67
Flink, 2006^121^ Peginterferon alfa-2b, 14 + Lamivudine, 100 vs. Peginterferon alfa-2b, 14 | 52/52 | HBeAg clearance | Previous treatment: LAM | 0.25 (0.03; 2.25) | -0.02 (-0.05; 0.01) | -52
Flink, 2006^121^ Peginterferon alfa-2b, 14 + Lamivudine, 100 vs. Peginterferon alfa-2b, 14 | 52/52 | HBV DNA <400 copies/mL | Previous treatment: LAM | 3.06 (0.13; 74.50) | 0.01 (-0.01; 0.02) | 152
Flink, 2006^121^ Peginterferon alfa-2b, 14 + Lamivudine, 100 vs. Peginterferon alfa-2b, 14 | 52/52 | HBeAg clearance | Previous treatment: IFN and LAM | 1.02 (0.15; 7.15) | 0.00 (-0.03; 0.03) | 3926
Flink, 2006^121^ Peginterferon alfa-2b, 14 + Lamivudine, 100 vs. Peginterferon alfa-2b, 14 | 52/52 | HBV DNA <400 copies/mL | Previous treatment: IFN and LAM | | 0.00 (-0.01; 0.01)
Flink, 2006^121^ Peginterferon alfa-2b, 14 + Lamivudine, 100 vs. Peginterferon alfa-2b, 14 | 52/52 | HBeAg clearance | Previous treatment: IFN | 1.63 (0.55; 4.88) | 0.02 (-0.02; 0.07) | 49
Flink, 2006^121^ Peginterferon alfa-2b, 14 + Lamivudine, 100 vs. Peginterferon alfa-2b, 14 | 52/52 | HBV DNA <400 copies/mL | Previous treatment: IFN | 5.10 (0.25; 105.32) | 0.01 (-0.01; 0.04) | 76
Flink, 2006^121^ Peginterferon alfa-2b, 14 + Lamivudine, 100 vs. Peginterferon alfa-2b, 14 | 52/52 | HBeAg clearance | Naive | 0.94 (0.63; 1.40) | -0.01 (-0.11; 0.08) | -67
HBV DNA <400 copies/mL | Naive | 1.02 (0.42; 2.50) | 0.00 (-0.05; 0.05) | 873
Janssen, 2005^78^ Peginterferon alfa-2b, 14 + Lamivudine, 100 vs. peginterferon alfa-2b, 14 | 52/52 | Adjusted odds ratio of sustained HBeAg loss | Absence of previous interferon therapy | 2.20 (1.10; 4.50)
Zhao, 2007^81^ Peginterferon alfa-2b, 11 vs. Interferon Alfa 2b, 1 | 24/24 | Multivariate adjusted odds ratio of sustained combined response: HBeAg negative, HBV DNA <5 log10 copies/mL, and normal ALT level | Pegylated IFN-a-2b vs. FN-a-2b | 1.73 (0.72; 4.14)
Bonino, 2007^114^ Peginterferon alfa-2a, 26 + Lamivudine, 100 vs. Lamivudine, 100 | 48/48 | Adjusted odds ratios of sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | PEG-IFNa-2a+LAM vs. LAM | 2.16 (1.14; 4.10)
Bonino, 2007^114^ Peginterferon alfa-2a, 26 + Lamivudine, 100 vs. Interferon Alfa 2b, 26 | 48/48 | Adjusted odds ratios of sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | PEG-IFNa-2a+LAM vs. PEG-IFNa-2a | 1.19 (0.80; 1.90)
Bonino, 2007^114^ Peginterferon alfa-2a, 26 + Lamivudine, 100 vs. Lamivudine, 100 | 48/48 | Adjusted odds ratios of sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | PEG-IFNa-2a+LAM vs. LAM | 2.19 (1.30; 3.60)
Bonino, 2007^114^ Peginterferon alfa-2a, 26 + Placebo,. vs. Lamivudine, 100 | 48/48 | Adjusted odds ratios of sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | PEG-IFNa-2a vs. LAM | 1.84 (1.10; 3.00)
PEG-IFNa-2a vs. LAM | 2.11 (1.11; 4.01)
Response to the treatment
van Zonneveld, 2006^125^ Peginterferon alfa-2b, 14 + Lamivudine, 100 vs. Peginterferon alfa-2b, 14 | 52/52 | Improved fibrosis scores as decrease of at least 1 point for the fibrosis score (range 0–6) | ALT normalization | 1.87 (0.71; 4.93) | 0.03 (-0.02; 0.08) | 30
Improved inflammatory changes in the liver as decrease of at least 2 points for the necroinflammatory score (range 0–18) | ALT normalization | 1.02 (0.53; 1.96) | 0.00 (-0.07; 0.07) | 491
Lau, 2005^56^ Peginterferon alfa-2a, 26 + Placebo vs. Lamivudine, 100 | 48/48 | HBeAg Seroconversion | Maximum ALT during treatment >10 ULN | 6.69 (2.01; 22.26) | 0.06 (0.03; 0.10) | 16
Lau, 2005^56^ Peginterferon alfa-2a, 26 + Placebo vs. Lamivudine, 100 | 48/48 | HBeAg Seroconversion | Maximum ALT during treatment >5–10 ULN | 1.76 (0.97; 3.17) | 0.04 (0.00; 0.09) | 22
Lau, 2005^56^ Peginterferon alfa-2a, 26 + Placebo vs. Lamivudine, 100 | 48/48 | HBeAg Seroconversion | Maximum ALT during treatment ≤5 ULN | 1.19 (0.77; 1.83) | 0.02 (-0.03; 0.08) | 44
Lau, 2005^56^ Peginterferon alfa-2a, 26 + Placebo vs. Lamivudine, 100 | 48/48 | HBeAg Seroconversion | Maximum ALT during treatment >5–10 ULN | 0.96 (0.58; 1.59) | 0.00 (-0.05; 0.05) | -271
Lau, 2005^56^ Peginterferon alfa-2a, 26 + Placebo vs. Lamivudine, 100 | 48/48 | HBeAg Seroconversion | Maximum ALT during treatment ≤5 ULN | 0.90 (0.59; 1.37) | -0.01 (-0.07; 0.04) | -68
Maximum ALT during treatment >10 ULN | 0.60 (0.30; 1.20) | -0.03 (-0.07; 0.01) | -34
Lau, 2005^56^ Peginterferon alfa-2a, 26 + Lamivudine, 100 vs. Lamivudine, 100 | 48/48 | HBeAg Seroconversion | Maximum ALT during treatment >10 ULN | 4.01 (1.15; 14.07) | 0.03 (0.01; 0.06) | 30
Lau, 2005^56^ Peginterferon alfa-2a, 26 + Lamivudine, 100 vs. Lamivudine, 100 | 48/48 | HBeAg Seroconversion | Maximum ALT during treatment >5–10 ULN | 1.69 (0.93; 3.07) | 0.04 (0.00; 0.09) | 25
Maximum ALT during treatment ≤5 ULN | 1.06 (0.68; 1.66) | 0.01 (-0.05; 0.06) | 128
Gish, 2007^101^ Entecavir, 0.50 vs. Lamivudine, 100 | 52/52 | Normalization of ALT levels (<1 ULN) | Responders (HBV DNA level 0.7 MEq/mL and loss of HBeAg) in year 1 | 1.19 (0.92; 1.55) | 0.11 (-0.05; 0.27) | 9
Gish, 2007^101^ Entecavir, 0.50 vs. Lamivudine, 100 | 96/96 | Normalization of ALT levels (<1 ULN) | Responders (HBV DNA 0.7 MEq/mL and loss of HBeAg) in year 2 | 0.90 (0.63; 1.29) | -0.07 (-0.31; 0.17) | -14
Gish, 2007^101^ Entecavir, 0.50 vs. Lamivudine, 100 | 52/52 | HBeAg Seroconversion | Responders (HBV DNA level 0.7 MEq/mL and loss of HBeAg) in year 1 | 1.11 (0.89; 1.39) | 0.07 (-0.08; 0.23) | 14
Gish, 2007^101^ Entecavir, 0.50 vs. Lamivudine, 100 | 52/52 | HBV DNA level 300 copies/mL by PCR | Responders (HBV DNA level 0.7 MEq/mL and loss of HBeAg) in year 1 | 1.18 (0.73; 1.90) | 0.05 (-0.10; 0.21) | 19
Gish, 2007^101^ Entecavir, 0.50 vs. Lamivudine, 100 | 96/96 | HBeAg Seroconversion | Responders (HBV DNA 0.7 MEq/mL and loss of HBeAg) in year 2 | 0.95 (0.59; 1.53) | -0.02 (-0.28; 0.23) | -40
96/96 | HBV DNA level 300 copies/mL by PCR | Responders (HBV DNA 0.7 MEq/mL and loss of HBeAg) in year 2 | 1.12 (0.41; 3.05) | 0.02 (-0.18; 0.23) | 42
Bonino, 2007^114^ Peginterferon alfa-2a, 26 vs. Lamivudine, 100 | 48/48 | Adjusted odds ratios of sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | End-of-treatment HBV DNA, per 1 log decrease | 2.90 (1.10; 7.70)
Chan, 2005^117^ Peginterferon alfa-2b, 14 + Lamivudine, 100 vs. Lamivudine, 100 | 60/52 | Transient elevation of HBV DNA to 100,000 copies/mL | Sustained responders as sustained HBeAg loss and HBV DNA <100,000 copies/mL | 0.50 (0.10; 2.61) | -0.04 (-0.13; 0.05) | -25
van Zonneveld, 2006^125^ Peginterferon alfa-2b, 14 + Lamivudine, 100 vs. Peginterferon alfa-2b, 14 | 52/52 | Improved inflammatory changes in the liver as decrease of at least 2 points for the necroinflammatory score (range 0–18) | No HBV DNA loss (PCR positive) | 0.44 (0.23; 0.83) | -0.10 (-0.18; -0.03) | -10
van Zonneveld, 2006^125^ Peginterferon alfa-2b, 14 + Lamivudine, 100 vs. Peginterferon alfa-2b, 14 | 52/52 | Improved fibrosis scores as decrease of at least 1 point for the fibrosis score (range 0–6) | No HBV DNA loss (PCR positive) | 1.02 (0.46; 2.28) | 0.00 (-0.06; 0.06) | 714
van Zonneveld, 2006^125^ Peginterferon alfa-2b, 14 + Lamivudine, 100 vs. Peginterferon alfa-2b, 14 | 52/52 | Improved inflammatory changes in the liver as decrease of at least 2 points for the necroinflammatory score (range 0–18) | No HBe Ag loss | 0.78 (0.39; 1.55) | -0.02 (-0.09; 0.04) | -41
van Zonneveld, 2006^125^ Peginterferon alfa-2b, 14 + Lamivudine, 100 vs. Peginterferon alfa-2b, 14 | 52/52 | Improved fibrosis scores as decrease of at least 1 point for the fibrosis score (range 0–6) | No HBe Ag loss | 1.87 (0.71; 4.93) | 0.03 (-0.02; 0.08) | 30
van Zonneveld, 2006^125^ Peginterferon alfa-2b, 14 + Lamivudine, 100 vs. Peginterferon alfa-2b, 14 | 52/52 | Improved inflammatory changes in the liver as decrease of at least 2 points for the necroinflammatory score (range 0–18) | HBV DNA loss (PCR negative) | 4.42 (1.28; 15.20) | 0.07 (0.02; 0.12) | 15
van Zonneveld, 2006^125^ Peginterferon alfa-2b, 14 + Lamivudine, 100 vs. Peginterferon alfa-2b, 14 | 52/52 | Improved Fibrosis scores as decrease of at least 1 point for the fibrosis score (range 0–6) | HBV DNA loss (PCR negative) | 3.06 (0.63; 14.92) | 0.03 (-0.01; 0.06) | 38
van Zonneveld, 2006^125^ Peginterferon alfa-2b, 14 + Lamivudine, 100 vs. Peginterferon alfa-2b, 14 | 52/52 | Improved inflammatory changes in the liver as decrease of at least 2 points for the necroinflammatory score (range 0–18) | HBeAg loss | 0.87 (0.42; 1.83) | -0.01 (-0.07; 0.05) | -88
Improved fibrosis scores as decrease of at least 1 point for the fibrosis score (range 0–6) | HBeAg loss | 0.87 (0.30; 2.54) | -0.01 (-0.05; 0.04) | -176
Lai, 2007^71^ Telbivudine, 600 vs. Lamivudine, 100 | 52/52 | Primary treatment failure -serum HBV DNA levels remained above 5 log 10 copies per milliliter | HBV DNA >4 log 10 copies/ml at week 24 in HBeAg-negative patients | 0.60 (0.48; 0.77) | -0.20 (-0.29; -0.11) | -5
Lai, 2007^71^ Telbivudine, 600 vs. Lamivudine, 100 | 52/52 | Primary treatment failure -serum HBV DNA levels remained above 5 log 10 copies per milliliter | HBV DNA >4 log 10 copies/ml at week 24 in HBeAg-positive patients | 0.64 (0.46; 0.89) | -0.06 (-0.11; -0.02) | -16
Lai, 2007^71^ Telbivudine, 600 vs. Lamivudine, 100 | 52/52 | Primary treatment failure -serum HBV DNA levels remained above 5 log 10 copies per milliliter | Undetectable HBV DNA at week 24 in HBeAg-negative patients | 0.11 (0.01; 2.07) | -0.02 (-0.04; 0.00) | -56
Lai, 2007^71^ Telbivudine, 600 vs. Lamivudine, 100 | 52/52 | Primary treatment failure -serum HBV DNA levels remained above 5 log 10 copies per milliliter | HBV DNA 3–4 log10 copies/ml at week 24 in HBeAg-negative patients | 0.19 (0.12; 0.31) | -0.31 (-0.38; -0.24) | -3
Lai, 2007^71^ Telbivudine, 600 vs. Lamivudine, 100 | 52/52 | Primary treatment failure -serum HBV DNA levels remained above 5 log 10 copies per milliliter | HBV DNA <3 log10 copies/ml at week 24 in HBeAg-negative patients | 0.29 (0.16; 0.53) | -0.14 (-0.20; -0.08) | -7
Lai, 2007^71^ Telbivudine, 600 vs. Lamivudine, 100 | 52/52 | Primary treatment failure -serum HBV DNA levels remained above 5 log 10 copies per milliliter | Undetectable HBV DNA at week 24 in HBeAg-positive patients | 0.36 (0.13; 0.99) | -0.02 (-0.04; 0.00) | -52
Lai, 2007^71^ Telbivudine, 600 vs. Lamivudine, 100 | 52/52 | Primary treatment failure -serum HBV DNA levels remained above 5 log 10 copies per milliliter | HBV DNA 3–4 log10 copies/ml at week 24 in HBeAg-positive patients | 0.45 (0.31; 0.65) | -0.10 (-0.14; -0.06) | -10
HBV DNA <3 log10 copies/ml at week 24 in HBeAg-positive patients | 0.20 (0.10; 0.40) | -0.08 (-0.11; -0.05) | -13

Table E10 Summary tables of the effects of therapies for CHB in patient subpopulations by baseline status of chronic hepatitis B

Outcome | Comparison | Weeks of Treatments/Followup off the Treatment | N Studies/Enrolled | Author | Relative Risk or Odds ratios (95% CI) | Comments
Baseline histology, outcomes at the end of the treatment
Overall disease progression - an increase of at least 2 points in the Child-Pugh score (5 indicates good and 15 -poor liver function) | Lamivudine vs. placebo | 130/0 | 1/651 | Liaw, 2004^51^ | 0.44 (0.23; 0.84) | disease progression was lowered among patients with baseline Child-Pugh score=5
Overall disease progression - an increase of at least 2 points in the Child-Pugh score (5 indicates good and 15 -poor liver function) | Lamivudine vs. placebo | 130/0 | 1/651 | Liaw, 2004^51^ | 0.37 (0.16; 0.86) | disease progression was lowered among patients with baseline Child-Pugh score=6
Overall disease progression - an increase of at least 2 points in the Child-Pugh score (5 indicates good and 15 -poor liver function) | Lamivudine vs. placebo | 130/0 | 1/651 | Liaw, 2004^51^ | 0.37 (0.19; 0.71) | disease progression was lowered among patients with baseline Ishak fibrosis score=6
Random differences among patients with baseline Child-Pugh score >7 and Ishak fibrosis score <4 or 5
Adjusted for treatment OR of HBeAg Loss | Lamivudine vs. placebo | 52/0 | 1/602 | Perrillo, 2002^104^ | 1.17 (1.10; 1.24) | HBeAg loss was higher per 1 unit increase in baseline HAI score
HBeAg loss irrespective of HBV-DNA status at baseline or week 56 | Lamivudine vs. placebo | 52/0 | 1/602 | Perrillo, 2002^104^ | 1.45 (0.40; 5.29) | HBeAg loss did not differ after lamivudine vs. placebo among the patients with pretreatment HAI Score 0–4
HBeAg loss irrespective of HBV-DNA status at baseline or week 56 | Lamivudine vs. placebo | 52/0 | 1/602 | Perrillo, 2002^104^ | 4.02 (1.23; 13.16) | HBeAg loss was higher among the patients with baseline HAI Score 5–9
2.27 (1.28; 4.02) | HBeAg loss was higher among the patients with baseline HAI Score >10
Worsening of Knodell necroinflammatory score | Lamivudine vs. placebo | 48/0 | 1/216 | Lai, 1998^50^ | 0.11 (0.03; 0.51) | Worsening of Knodell necroinflammatory score after lamivudine vs. placebo was less frequent among patients with moderate or severe hepatitis
Histological response - reduction of 2 or more points in the Knodell necroinflammatory score between baseline and week 52 | Lamivudine vs. placebo | 48/0 | 1/216 | Lai, 1998^50^ | 2.30 (1.39; 3.81) | Lamivudine improved histology compared to placebo among the patients with moderate or severe hepatitis
| | | 2.17 (0.76; 6.21) | Lamivudine did not improve histology compared to placebo among the patients with mild hepatitis
Baseline viral load, outcomes at the end of the treatment
HBeAg loss, loss of detectable HBV DNA, and seroconversion to antiHBeAg | Interferon Alfa 2b+lamivudine vs. lamivudine | 52/0 | 1/75 | Sarin, 2005^69^ | 2.92 (0.63; 13.56) | Random differences among the patients with baseline HBV DNA >107 copies/mL
HBeAg loss | Interferon Alfa 2b+lamivudine vs. lamivudine | 52/0 | 1/75 | Sarin, 2005^69^ | 1.62 (0.66; 4.01) | Random differences among patients with baseline HBV DNA >107 copies/mL
HBeAg loss with antiHBeAg appearance | 2.92 (0.63; 13.56) | Random differences among patients with baseline HBV DNA >107 copies/mL
HBeAg loss | Interferon Alfa 2b vs. no treatment | 32/0 | 1/118 | Janssen, 1999^83^ | 4.20 (0.95; 18.64) | Random differences among the patients with baseline HBV DNA <10pg/ml
0.19 (0.01; 3.82) | Random differences among patients with baseline HBV DNA >10pg/ml
OR of hepatic decompensation: change in the Child-Turcotte-Pugh score of 2 or more points adjusted for treatments, ALT, HBV DNA, sex, YMDD variant, platelet, bilirubin, albumin | Lamivudine vs. no treatment | 80/0 | 1/74 | Kim, 2006^54^ | Random association with baseline HBV DNA
OR of flare - elevation of ALT activity to >10 times the ULN and to > twice the baseline value with detectable HBV DNA- adjusted for treatments, ALT, HBV DNA, sex, YMDD variant, platelet, bilirubin, albumin | Lamivudine vs. no treatment | 80/0 | 1/74 | Kim, 2006^54^ | Random association with baseline HBV DNA
Overall disease progression - an increase of at least 2 points in the Child-Pugh score | Lamivudine vs. placebo | 130/0 | 1/651 | Liaw, 2004^51^ | 0.22 (0.07; 0.70) | Disease progression was lower among the patients with baseline HBV DNA below the lower limit of quantitation
Overall disease progression - an increase of at least 2 points in the Child-Pugh score | Lamivudine vs. placebo | 130/0 | 1/651 | Liaw, 2004^51^ | 0.77 (0.34; 1.74) | Disease progression was not lower among the patients with baseline HBV DNA 0.7–10 meq/ml
Overall disease progression - an increase of at least 2 points in the Child-Pugh score | Lamivudine vs. placebo | 130/0 | 1/651 | Liaw, 2004^51^ | 0.37 (0.13; 1.05) | Disease progression was lower among the patients with baseline HBV DNA >10–100 meq/ml
0.41 (0.18; 0.94) | Disease progression was lower among the patients with baseline HBV DNA >100 meq/ml
Adjusted for treatments odds ratio of HBeAg loss | Lamivudine vs. placebo | 52/0 | 1/602 | Perrillo, 2002^104^ | 0.99 (0.97; 1.00) | HBeAg loss was not associated with baseline HBV-DNA level (per 10-unit increase)
HBV DNA loss | Lamivudine vs. placebo | 12/0 | 1/429 | Yao, 1999^112^ | 6.41 (3.92; 10.47) | HBV DNA loss among patients with baseline HBV DNA >1.6pg/ml
Adjusted OR of sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | Peginterferon alfa-2a vs. lamivudine | 48/0 | 1/1036 | Bonino, 2007^114^ | 1.28 (1.10; 1.40) | Sustained combined response was increased by 1 log 10 unit (copies/ml) decrease in baseline HBV DNA
Baseline HBeAg status, outcomes at the end of the treatment
Overall disease progression - an increase of at least 2 points in the Child-Pugh score | Lamivudine vs. placebo | 130/0 | 1/651 | Liaw, 2004^51^ | 0.72 (0.36; 1.43) | lamivudine did not decrease compared to placebo disease progression among HBeAg- at baseline patients
0.30 (0.16; 0.55) | lamivudine decreased compared to placebo disease progression among HBeAg+ at baseline patients
Undetectable HBV DNA level by bDNA assay and normal ALT level | Entecavir (dose) | 48/0 | 1/182 | Change, 2005^76^ | No dose response association among patients with baseline HBeAg + or HBeAg - status
Undetectable HBV DNA level by bDNA assay and normal ALT level | Entecavir vs. lamivudine | 48/0 | 1/182 | Change, 2005^76^ | 18.38 (1.18; 285.96) | entecavir in dose 1 mg/day vs. lamivudine resulted in higher rates of undetectable HBV DNA level by bDNA assay and normal ALT level among the patients with HBeAg- baseline status
Undetectable HBV DNA level by bDNA assay and normal ALT level | Entecavir vs. lamivudine | 48/0 | 1/182 | Change, 2005^76^ | Entecavir in doses 0.5 or 0.1mg/day did not result in significant differences compared to lamivudine
1.19 (0.18; 7.86) | entecavir in dose 1, 0.5, or 0.1 mg/day vs. lamivudine did not result in higher rates of undetectable HBV DNA level by bDNA assay and normal ALT level among the patients with HBeAg+ baseline status
HBV DNA >4 log 10 copies/ml | Telbivudine vs. lamivudine | 52/0 | 1/1367 | Lai, 2007^71^ | 0.55 (0.27; 1.13) | No differences between telbivudine vs. lamivudine among patients with HBeAg- status at baseline
0.67 (0.54; 0.82) | telbivudine vs. lamivudine reduced the rates of detectable HBV DNA among the patients with HBeAg+ baseline status
ALT normalization | Telbivudine vs. lamivudine | 52/0 | 1/1367 | Lai, 2007^71^ | 0.94 (0.84; 1.04) | No differences between telbivudine vs. lamivudine among patients with HBeAg- status at baseline
1.03 (0.96; 1.11) | No differences between telbivudine vs. lamivudine among patients with HBeAg+ status at baseline
HBV DNA <3 log 10 copies/ml | Telbivudine vs. lamivudine | 52/0 | 1/1367 | Lai, 2007^71^ | 0.91 (0.49; 1.67) | No differences between telbivudine vs. lamivudine among patients with HBeAg- status at baseline
0.93 (0.67; 1.29) | No differences between telbivudine vs. lamivudine among patients with HBeAg+ status at baseline
Ishak fibrosis scores improved | Telbivudine vs. lamivudine | 52/0 | 1/1367 | Lai, 2007^71^ | 1.28 (1.07; 1.54) | telbivudine vs. lamivudine improved fibrosis scores among patients with HBeAg - status at baseline
1.11 (1.01; 1.23) | RR, telbivudine vs. lamivudine improved fibrosis scores among patients with HBeAg+ status at baseline
Primary treatment failure -serum HBV DNA levels remained above 5 log 10 copies per milliliter | Telbivudine vs. lamivudine | 52/0 | 1/1367 | Lai, 2007^71^ | 0.17 (0.02; 1.39) | No differences between telbivudine vs. lamivudine among patients with HBeAg-status at baseline
0.36 (0.22; 0.57) | telbivudine vs. lamivudine reduced the rates of treatment failure among patients with HBeAg + at baseline
Reduction of at least 2 points in the Knodell necroinflammatory score, with no worsening in the fibrosis score | Telbivudine vs. lamivudine | 52/0 | 1/1367 | Lai, 2007^71^ | 1.01 (0.88; 1.15) | no differences between telbivudine vs. lamivudine among patients with HBeAg- status at baseline
1.15 (1.03; 1.27) | telbivudine vs. lamivudine improved necroinflammatory score, with no worsening in the Knodell fibrosis score among patients with HBeAg +status at baseline
Serum HBV DNA undetectable by PCR | Telbivudine vs. lamivudine | 52/0 | 1/1367 | Lai, 2007^71^ | 1.24 (1.12; 1.36) | telbivudine vs. lamivudine increased HBV DNA loss among patients with HBeAg -status at baseline
1.49 (1.30; 1.70) | telbivudine vs. lamivudine increased HBV DNA loss among patients with HBeAg + status at baseline
Viral breakthrough - at least 2 consecutive determinations of an increase in HBV DNA by at least 1 log10 copy per milliliter from nadir | Telbivudine vs. lamivudine | 52/0 | 1/1367 | Lai, 2007^71^ | 0.18 (0.07; 0.46) | telbivudine vs. lamivudine reduced the rates of viral breakthrough among patients with HBeAg -status at baseline
0.38 (0.25; 0.59) | telbivudine vs. lamivudine reduced the rates of viral breakthrough among patients with HBeAg + status at baseline
Viral breakthrough - at least 2 consecutive determinations of an increase in HBV DNA by at least 1 log10 copy per milliliter from nadir with treatment-emergent resistance mutations | Telbivudine vs. lamivudine | 52/0 | 1/1367 | Lai, 2007^71^ | 0.21 (0.08; 0.54) | telbivudine vs. lamivudine reduced the rates of viral breakthrough among patients with HBeAg -status at baseline
0.46 (0.28; 0.73) | telbivudine vs. lamivudine reduced the rates of viral breakthrough among patients with HBeAg + status at baseline
Genotype, outcomes at the end of the treatment
Adjusted OR of sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | Peginterferon alfa-2a vs. lamivudine | 48/0 | 1/1036 | Bonino, 2007^114^ | 0.42 (0.10; 1.20) | No differences in sustained response between genotype A vs. B
Adjusted OR of sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | Peginterferon alfa-2a vs. lamivudine | 48/0 | 1/1036 | Bonino, 2007^114^ | 0.33 (0.10; 0.90) | Patients with genotype A vs. C had lower adjusted rates of sustained response
Adjusted OR of sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | Peginterferon alfa-2a vs. lamivudine | 48/0 | 1/1036 | Bonino, 2007^114^ | 0.97 (0.30; 2.70) | No differences in sustained response between genotype A vs. D
Adjusted OR of sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | Peginterferon alfa-2a vs. lamivudine | 48/0 | 1/1036 | Bonino, 2007^114^ | 0.79 (0.50; 1.30) | No differences in sustained response between genotype B vs. C
Adjusted OR of sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | Peginterferon alfa-2a vs. lamivudine | 48/0 | 1/1036 | Bonino, 2007^114^ | 2.31 (1.30; 4.20) | Patients with genotype B vs. D had higher adjusted rates of sustained response
2.90 (1.70; 5.00) | Patients with genotype C vs. D had higher adjusted rates of sustained response
YMDD mutation, outcomes at the end of the treatment
OR of flare - elevation of ALT activity to >10 times the ULN and to > twice the baseline value with detectable HBV DNA-adjusted for treatments, ALT, HBV DNA, sex, YMDD variant, platelet, bilirubin, albumin | Lamivudine vs. no treatment | 80/0 | 1/74 | Kim, 2006^54^ | Random association with YMDD mutation
OR of hepatic decompensation change in the Child-Turcotte-Pugh score of 2 or more points adjusted for treatments, ALT, HBV DNA, sex, YMDD variant, platelet, bilirubin, albumin | Lamivudine vs. no treatment | 80/0 | 1/74 | Kim, 2006^54^ | Random association with YMDD mutation
Change in necroinflammation: worsening | Lamivudine vs. placebo | 48/0 | 1/85 | Yuen, 2005^111^ | 0.15 (0.04; 0.54) | Lamivudine vs. placebo reduced the rates of worsened histology among patients without YMDD mutation
0.18 (0.01; 2.87) | Lamivudine vs. placebo did not reduce the rates of worsened histology among patients with YMDD mutation
Change in fibrosis: worsening | Lamivudine vs. placebo | 48/0 | 1/85 | Yuen, 2005^111^ | 0.90 (0.27; 2.98) | Lamivudine vs. placebo did not reduce the rates of worsened histology among patients without YMDD mutation
0.86 (0.11; 6.92) | Lamivudine vs. placebo did not reduce the rates of worsened histology among patients with YMDD mutation
Change in necroinflammation: Improvement | Lamivudine vs. Placebo | 48/0 | 1/85 | Yuen, 2005^111^ | 3.30 (1.15; 9.51) | Lamivudine vs. placebo improved histology among patients without YMDD mutation
3.43 (1.02; 11.57) | Lamivudine vs. placebo improved histology among patients with YMDD mutation
Change in fibrosis: Improvement | Lamivudine vs. placebo | 48/0 | 1/85 | Yuen, 2005^111^ | 0.30 (0.02; 4.56) | Lamivudine vs. placebo did not improve fibrosis scores among patients without YMDD mutation
0.79 (0.04; 17.44) | Lamivudine vs. placebo did not improve fibrosis scores among patients with YMDD mutation
Baseline ALT, at followup off the treatment
Active hepatitis | Interferon Alfa 2b+corticosteroid vs. interferon Alfa 2b | 24/24 | 1/56 | Zarski, 1994^91^ | 0.81 (0.22; 2.91) | random differences among patients with baseline ALT <3ULN
Cirrhosis | Interferon Alfa 2b+corticosteroid vs. interferon Alfa 2b | 24/24 | 1/56 | Zarski, 1994^91^ | 0.40 (0.04; 4.19) | random differences among patients with baseline ALT <3ULN
HBV DNA loss | Interferon Alfa 2b+corticosteroid vs. interferon Alfa 2b | 24/24 | 1/115 | Wai, 2002^102^ | 1.22 (1.05; 1.42) | HBV DNA loss was more frequent among patients with elevated baseline ALT
1/56 | Zarski, 1994^91^ | 2.42 (0.27; 21.86) | random differences among patients with baseline ALT <3ULN
Loss of HBV DNA + HBeAg seroconversion | Interferon Alfa 2b+corticosteroid vs. interferon Alfa 2b | 24/24 | 2/95 | Zarski, 1994^91^ | Random changes in both studies among elevated ALT
Lok, 1992^93^
Loss of HBV DNA and HBeAg | Interferon Alfa 2b+corticosteroid vs. interferon Alfa 2b | 24/24 | 1/85 | Perrillo, 1990^96^ | Random changes in all groups with elevated ALT level
Loss of HBV DNA, HBeAg, and HBsAg | Interferon Alfa 2b+corticosteroid vs. interferon Alfa 2b | 24/24 | 1/39 | Lok, 1992^93^ | 0.29 (0.01; 6.66) | random differences among patients with elevated baseline ALT
HBsAg loss | Interferon Alfa 2b+corticosteroid vs. interferon Alfa 2b | 24/24 | 1/56 | Zarski, 1994^91^ | 3.23 (0.38; 27.06) | random differences among patients with baseline ALT <3ULN
Loss of HBV DNA + HBeAg seroconversion | Interferon Alfa 2b+corticosteroid vs. no treatment | 24/24 | 1/37 | Lok, 1992^93^ | 2.29 (0.74; 7.10) | random differences among patients with elevated baseline ALT
Loss of HBV DNA, HBeAg, and HBsAg | Interferon Alfa 2b+corticosteroid vs. no treatment | 24/24 | 1/37 | Lok, 1992^93^ | 0 events in both treatment groups
Loss of HBV DNA and HBeAg | Interferon Alfa 2b+corticosteroid vs. no treatment | 24/24 | 1/43 | Perrillo, 1990^96^ | 7.82 (1.02; 59.88) | Loss of HBV DNA and HBeAg was greater among patients with baseline ALT <100U/L with random differences among those with baseline ALT100–200 and >200U/L
HBeAg loss | Interferon Alfa 2b+lamivudine vs. interferon Alfa 2b | 24/28 | 1/203 | Perrillo, 2002^104^ | Random differences among patients with baseline ALT <1ULN, 2–5ULN, and >5 ULN
HBeAg seroconversion | Interferon Alfa 2b+lamivudine vs. interferon Alfa 2b | 24/28 | 2/347 | Schalm, 2000^67^ | Random differences among patients with baseline ALT <1ULN, 2–5ULN, and >5 ULN
Perrillo, 2002^104^
Odds ratio of sustained virologic response (sustained suppression of serum levels of HBeAg and HBV DNA) in those with baseline ALT levels of 150 or more independent of gender and age | Interferon Alfa 2b+lamivudine vs. lamivudine | 24/48 | 1/150 | Barbaro, 2001^66^ | 3.12 (1.43; 6.82) | Adjusted odds of virologic response were higher in patients with baseline ALT >150UL
HBeAg loss | Interferon Alfa 2b+lamivudine vs. lamivudine | 24/28 | 1/541 | Perrillo, 2002^104^ | Random differences among patients with baseline ALT <1ULN, 2–5ULN, and >5 ULN
HBeAg seroconversion | Interferon Alfa 2b+lamivudine vs. lamivudine | 24/28 | 2/698 | Perrillo, 2002^104^ | Random differences among patients with baseline ALT <1ULN, 2–5ULN, and >5 ULN
Schalm, 2000^67^
HBeAg loss | Interferon Alfa 2b+lamivudine vs. placebo | 24/28 | 1/331 | Perrillo, 2002^104^ | 2.90 (1.35; 6.27) | HBeAg loss was higher among patients with ALT >2 but <5ULN with random differences among those with <1ULN or 1–2ULN
HBeAg seroconversion | Interferon Alfa 2b+lamivudine vs. placebo | 24/28 | 1/331 | Perrillo, 2002^104^ | 2.70 (1.10; 6.58) | HBeAg seroconversion was greater among patients with >2-<5 ULN
3.27 (1.03; 10.39) | HBeAg seroconversion was greater among patients with ALT >5 ULN with random differences among those with baseline ALT<1ULN or 1–2ULN
HBeAg seroconversion | Interferon Alfa 2b+placebo vs. lamivudine | 24/28 | 1/151 | Schalm, 2000^67^ | Random differences among patients with baseline ALT <2, 2–5, or >5ULN
Partial antiviral response: sustained clearance of serum HBV DNA by direct spot hybridization (lower limit of detection of 10 pg/mL) and clearance of HBeAg but not HBsAg | Interferon Alfa 2b+placebo vs. no treatment | 24/24 | 1/34 | Lok, 1992^93^ | 1.48 (0.42; 5.24) | Random differences in patients with elevated ALT
Complete antiviral response: sustained clearance of serum HBV DNA by direct spot hybridization (lower limit of detection of 10 pg/mL) and clearance of HBeAg and HBsAg | | 24/24 | 1/34 | Lok, 1992^93^ | 2.68 (0.12; 61.58) | Random differences in patients with elevated ALT
HBeAg loss | Interferon Alfa 2b vs. lamivudine | 24/28 | 1/474 | Perrillo, 2002^104^ | Random differences among patients with baseline ALT <1ULN, 2–5ULN, and >5 ULN
HBeAg seroconversion | Interferon Alfa 2b vs. lamivudine | 24/28 | 1/474 | Perrillo, 2002^104^ | Random differences among patients with baseline ALT <1ULN, 2–5ULN, and >5 ULN
Loss of HBV DNA and HBeAg | Interferon Alfa 2b vs. no treatment | 24/24 | 1/84 | Perrillo, 1990^96^ | Random differences among patients with baseline ALT <100, 100–200, and >200U/L
HBeAg loss | Interferon Alfa 2b vs. placebo | 24/28 | 0/264 | Perrillo, 2002^104^ | Random differences among patients with baseline ALT <1ULN, 2–5ULN, and >5 ULN
HBeAg seroconversion | | 24/28 | 0/264 | Perrillo, 2002^104^ | Random differences among patients with baseline ALT <1ULN, 2–5ULN, and >5 ULN
Sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | Peginterferon alfa-2a+lamivudine vs. lamivudine | 48/24 | 1/202 | Bonino, 2007^114^ | Random differences among patients with baseline ALT 2–5 and >5 ULN
Adjusted for treatment status odds ratio of sustained response: HBeAg seroconversion, HBV DNA loss and ALT normalization in HBeAg (+) patients. In HBeAg (-) patients: loss of HBV DNA+ALT normalization | peginterferon alfa-2a+lamivudine vs. lamivudine | 9/24 | 1/140 | Cindoruk, 2007^115^ | 10.32 (9.71; 10.97) | Sustained response was greater per increase in 1unit (U/L) in baseline ALT
HBeAg seroconversion | Peginterferon alfa-2a+lamivudine vs. lamivudine | 48/24 | 1/542 | Lau, 2005^56^ | 1.93 (1.01; 3.69) | Response was greater among patients with baseline ALT >5ULN, random differences among those with baseline ALT <2 or 2–5ULN
HBeAg seroconversion | Peginterferon alfa-2a+lamivudine vs. peginterferon alfa-2a | 48/24 | 1/542 | Lau, 2005^56^ | Random differences among patients with baseline ALT <2, 2–5, and >5 ULN
Sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | Peginterferon alfa-2a+placebo vs. lamivudine | 48/24 | 1/202 | Bonino, 2007^114^ | Random differences among patients with baseline ALT <2, 2–5, and >5 ULN
HBeAg seroconversion | Peginterferon alfa-2a+placebo vs. lamivudine | 48/24 | 1/542 | Lau, 2005^56^ | 1.81 (1.07; 3.04) | HBeAg seroconversion was greater in patients with baseline ALT >2 but <5ULN. Random differences among those with baseline ALT <2 or >5ULN
Adjusted odds ratios of sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | Peginterferon alfa-2a vs. lamivudine | 48/24 | 1/1036 | Bonino, 2007^114^ | Random association per 1 U/L increase in baseline ALT
Adjusted for treatment allocation, hepatitis B virus (HBV) genotype and log HBV DNA odds ratio of persistent HBeAg loss at any time up to week 76 of post-treatment followup | Peginterferon alfa-2b+lamivudine vs. lamivudine | 60/24 | 1/100 | Chan, 2006^118^ | Random association per 1 U/L increase in baseline ALT
Adjusted for treatment allocation, HBV DNA genotype, IL-1b-511 polymorphism, baseline log HBV DNA odds ratio of persistent HBeAg loss and at any time up to week 76 of post-treatment followup | Peginterferon alfa-2b+lamivudine vs. lamivudine | 60/24 | 1/100 | Chan, 2006^118^ | Random association per 1 U/L increase in baseline ALT
Adjusted odds ratio of sustained HBeAg loss | Peginterferon alfa-2b+lamivudine vs. peginterferon alfa-2b | 52/26 | 1/310 | Janssen, 2005^78^ | Random differences among patients with elevated vs. normal baseline ALT
Multivariate adjusted odds ratio of sustained combined response: HBeAg negative, HBV DNA <5 log10 copies/mL, and normal ALT level | Peginterferon alfa-2b+vs. interferon Alfa 2b | 24/24 | 1/230 | Zhao, 2007^81^ | 1.23 (0.51; 2.92) | RR, random differences between patients with baseline ALT level >3.4 vs. <3.4 ULN
Baseline histology at followup off the treatment
HBeAg loss | Interferon Alfa 2b vs. placebo | 24/28 | 1/264 | Perrillo, 2002^104^ | 3.84 (0.88; 16.74) | Interferon Alfa 2b vs. placebo did not increase HBeAg loss among patients with pretreatment HAI score 0–4
HBeAg loss | Interferon Alfa 2b vs. placebo | 24/28 | 1/264 | Perrillo, 2002^104^ | 5.76 (1.48; 22.42) | Interferon Alfa 2b vs. placebo increased HBeAg loss among patients with pretreatment HAI score 5–9
1.11 (0.41; 2.99) | Interferon Alfa 2b vs. placebo did not increase HBeAg loss among patients with pretreatment HAI score >10
HBeAg loss | Interferon Alfa 2b+lamivudine vs. placebo | 24/28 | 1/331 | Perrillo, 2002^104^ | 3.39 (0.89; 12.87) | Interferon Alfa 2b+lamivudine vs. placebo did not increase HBeAg loss in patients with pretreatment HAI Score 0–4
HBeAg loss | Interferon Alfa 2b+lamivudine vs. placebo | 24/28 | 1/331 | Perrillo, 2002^104^ | 5.32 (1.51; 18.72) | Interferon Alfa 2b+lamivudine vs. placebo increased HBeAg loss in patients with pretreatment HAI Score 5–9
1.79 (0.89; 3.59) | Interferon Alfa 2b+lamivudine vs. placebo did not increase HBeAg loss in patients with pretreatment HAI Score >10
HBeAg loss | Interferon Alfa 2b vs. lamivudine | 24/28 | 1/331 | Perrillo, 2002^104^ | 2.65 (0.84; 8.38) | Interferon Alfa 2b vs. lamivudine did not increase HBeAg loss in patients with pretreatment HAI Score 0–4
HBeAg loss | Interferon Alfa 2b vs. lamivudine | 24/28 | 1/331 | Perrillo, 2002^104^ | 1.43 (0.61; 3.36) | Interferon Alfa 2b vs. lamivudine did not increase HBeAg loss in patients with pretreatment HAI Score 5–9
0.49 (0.20; 1.17) | Interferon Alfa 2b vs. lamivudine did not increase HBeAg loss in patients with pretreatment HAI score >10
Odds ratio of sustained virologic response (sustained suppression of serum levels of HBeAg and HBV DNA) in those with a baseline inflammation score of 7 or more independent on gender and age | Interferon Alfa 2b+ lamivudine vs. lamivudine | 24/48 | 1/151 | Barbaro, 2001^66^ | 2.91 (1.04; 8.22) | The rate of sustained response after interferon Alfa 2b+ lamivudine vs. lamivudine was increased by an increase in baseline inflammation scores
2.58 (0.88; 7.60) | The rate of sustained response after interferon Alfa 2b+ lamivudine vs. lamivudine was not increased by an increase in baseline fibrosis scores
HBeAg loss | Interferon Alfa 2b+ lamivudine vs. lamivudine | 24/28 | 1/541 | Perrillo, 2002^104^ | 2.34 (0.89; 6.16) | The rate of HBeAg loss after interferon Alfa 2b+ lamivudine vs. lamivudine was not different among patients with baseline HAI scores 0–4
HBeAg loss | Interferon Alfa 2b+ lamivudine vs. lamivudine | 24/28 | 1/541 | Perrillo, 2002^104^ | 1.32 (0.67; 2.62) | The rate of HBeAg loss after interferon Alfa 2b+ lamivudine vs. lamivudine was not different among patients with baseline HAI scores 5–9
0.79 (0.47; 1.32) | The rate of HBeAg loss after interferon Alfa 2b+ lamivudine vs. lamivudine was not different among patients with baseline HAI scores >10
HBeAg loss | Interferon Alfa 2b+lamivudine vs. interferon Alfa 2b | 24/52 | 1/203 | Perrillo, 2002^104^ | 0.88 (0.27; 2.91) | No differences between interferon Alfa 2b+lamivudine vs. interferon Alfa 2b among patients with baseline HAI scores 0–4
HBeAg loss | Interferon Alfa 2b+lamivudine vs. interferon Alfa 2b | 24/52 | 1/203 | Perrillo, 2002^104^ | 0.92 (0.36; 2.39) | No differences between interferon Alfa 2b+lamivudine vs. interferon Alfa 2b among patients with baseline HAI scores 5–9
1.61 (0.62; 4.21) | No differences between interferon Alfa 2b+lamivudine vs. interferon Alfa 2b among patients with baseline HAI scores >10
Adjusted for treatment status odds ratio of sustained response: HBeAg seroconversion, HBV DNA disappearance and ALT normalization in HBeAg (+) patients. In HBeAg (-) patients: loss of HBV DNA, ALT normalization | Peginterferon alfa-2a+lamivudine vs. lamivudine | 9/15 | 1/160 | Cindoruk, 2007^115^ | Presence of steatosis did not modify the effect of peginterferon alfa-2a + lamivudine vs. lamivudine on sustained response
14.97 (2.43; 92.28) | The adjusted rates of sustained response were increased per increase in baseline Knodell HAI
Adjusted relative risk of flares defined as an increase in serum ALT to at least 3 times the baseline level | Peginterferon alfa-2b+lamivudine vs. peginterferon alfa-2b | 52/78 | 1/310 | Flink, 2005^120^ | 2.00 (1.00; 4.00) | Preexisting cirrhosis increased adjusted relative risk of flares
Adjusted relative risk of HBeAg seroconversion and HBV DNA 10,000 copies/ml | Peginterferon alfa-2b+lamivudine vs. peginterferon alfa-2b | 52/78 | 1/310 | Buster, 2007^124^ | 0.98 (0.17; 5.23) | Presence of advanced fibrosis- fibrosis score of 4–6 (HAI) did not change adjusted relative risk of HBV DAN loss and HBeAg seroconversion
Baseline viral load at followup off the treatment
Negative HBV DNA with persistent HBeAg | Interferon Alfa 2b vs. no treatment | 32/20–52w | 1/118 | Janssen, 1999^83^ | 1.87 (0.59; 5.87) | no association between baseline positive HBV DNA (per 1 unit increase) and the effects of interferon Alfa 2b vs. no treatment
Loss of HBV DNA and HBeAg | Interferon Alfa 2b vs. no treatment | 24/24 | 1/169 | Perrillo, 1990^96^ | 5.24 (1.22; 22.50) | interferon Alfa 2b, 5MU/day vs. no treatment increased rates of HBV DNA and HBeAg loss among patients with baseline HBV DNA 2-99pg/ml. Random differences after interferon 1MU/day.
RR, random differences after interferon 1 or 5 MU/day among the patients with baseline HBV DNA 100–200 pg/ml or >200 pg/ml
HBeAg loss | Interferon Alfa 2b vs. No treatment | 32/20 | 1/118 | Janssen, 1999^83^ | 3.18 (1.25; 8.05) | RR, Interferon Alfa 2b, 10 MU three times per week vs. no treatments increased rates of HBeAg loss among the patients with baseline HBV DNA <10pg/ml. Random differences among the patients with baseline HBV DNA >10pg/ml
Loss of HBV DNA and HBeAg | Interferon Alfa 2b+corticosteroid vs. no treatment | 24/24 | 1/169 | Perrillo, 1990^96^ | 5.38 (1.26; 22.84) | interferon Alfa 2b+corticosteroid vs. no treatment increased rates of HBV and HBeAg loss among patients with baseline HBV DNA 2-99pg/ml
Loss of HBV DNA and HBeAg | Interferon Alfa 2b+corticosteroid vs. no treatment | 24/24 | 1/169 | Perrillo, 1990^96^ | 8.80 (0.49; 158.66) | interferon Alfa 2b+corticosteroid vs. no treatment did not increase the rates of HBV DNA and HBeAg loss among patients with baseline HBV DNA 100–200 pg/ml
0.98 (0.06; 15.13) | interferon Alfa 2b+corticosteroid vs. no treatment did not increase the rates of HBV DNA and HBeAg loss among patients with baseline HBV DNA >200 pg/ml
Loss of HBV DNA and HBeAg | Interferon Alfa 2b+Corticosteroid vs. Interferon Alfa 2b | 24/24 | 1/169 | Perrillo, 1990^96^ | Random differences after interferon Alfa 2b+Corticosteroid vs. interferon Alfa 2b in patients with baseline HBV DNA 2-99pg/ml, 100–200 pg/ml, or >200 pg/ml
HBeAg loss | Interferon Alfa 2b+corticosteroid vs. interferon Alfa 2b | 24/24 | 1/183 | Wai, 2002^102^ | 1.10 (1.03; 1.17) | Interferon Alfa 2b+corticosteroid vs. interferon Alfa 2b increased the rates of HBeAg loss in patients with low baseline HBV-DNA level
1.10 (1.01; 1.21) | Interferon Alfa 2b+corticosteroid vs. interferon Alfa 2b increased the rates of HBeAg loss in patients with low baseline HBV-DNA and elevated baseline ALT
Odds ratio of sustained virologic response | Interferon Alfa 2b+lamivudine vs. lamivudine | 24/48 | 1/151 | Barbaro, 2001^66^ | 7.23 (2.71; 19.57) | Odds of sustained suppression of serum levels of HBeAg and HBV DNA was significant in those with baseline viral load of 200 pg/ml or less independent of gender and age
HBeAg loss | Interferon Alfa 2b+lamivudine vs. lamivudine | 52/24 | 1/75 | Sarin, 2005^69^ | 3.89 (1.20; 12.69) | Interferon Alfa 2b+lamivudine vs. lamivudine resulted in increase rates of HBeAg loss in patients with baseline HBV DNA >107 copies/mL
HBeAg loss, HBeAg seroconversion | Interferon Alfa 2b+lamivudine vs. lamivudine | 52/24 | 1/75 | Sarin, 2005^69^ | 4.87 (1.14; 20.74) | Interferon Alfa 2b+lamivudine vs. lamivudine resulted in increase rates of HBeAg seroconversion and HBV DNA loss in patients with baseline HBV DNA >107 copies/mL
Viral breakthrough as the reappearance of serum HBV-DNA by solution hybridization assay in at least 2 consecutive tests during lamivudine therapy following the disappearance of the serum HBV DNA | Interferon Alfa 2b+lamivudine vs. lamivudine | 176/192 | 1/83 | Jang, 2004^65^ | Random association with baseline HBV DNA levels (1 unit increase)
Adjusted for treatment status odds ratio of sustained response: HBeAg seroconversion, HBV DNA disappearance and ALT normalization in HBeAg (+) patients. In HBeAg (-) patients: loss of HBV DNA, ALT normalization | Peginterferon alfa-2a+lamivudine vs. lamivudine | 9/6 | 1/140 | Cindoruk, 2007^115^ | 1.05 (0.13; 8.14) | Baseline mean viral load (copy/mL) was not associated with sustained response to the therapy
Sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | Peginterferon alfa-2a+lamivudine vs. lamivudine | 48/24 | 1/76 | Bonino, 2007^114^ | 2.24 (1.31; 3.83) | Peginterferon alfa-2a+lamivudine vs. lamivudine increased sustained response among patients with baseline HBV DNA <6.12 log10 copies/ml
Sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | Peginterferon alfa-2a+lamivudine vs. lamivudine | 48/24 | 1/76 | Bonino, 2007^114^ | 1.78 (1.11; 2.84) | Peginterferon alfa-2a+lamivudine vs. lamivudine increased sustained response among patients with baseline HBV DNA >6.12–8.42 log 10 copies/ml
1.37 (0.67; 2.80) | Peginterferon alfa-2a+lamivudine vs. lamivudine did not increase sustained response among patients with baseline HBV DNA >8.42 log 10 copies/ml
HBeAg seroconversion | Peginterferon alfa-2a+lamivudine vs. lamivudine | 48/24 | 1/543 | Lau, 2005^56^ | 0.84 (0.47; 1.48) | Peginterferon alfa-2a+lamivudine vs. lamivudine did not increase HBeAg seroconversion among patients with baseline HBV DNA levels ≤9.07 (log copies/ml)
HBeAg seroconversion | Peginterferon alfa-2a+lamivudine vs. lamivudine | 48/24 | 1/543 | Lau, 2005^56^ | 1.91 (1.16; 3.15) | Peginterferon alfa-2a+lamivudine vs. lamivudine increased HBeAg seroconversion among patients baseline HBV DNA levels >9.07–10.26 (log copies/ml)
2.01 (0.82; 4.90) | Peginterferon alfa-2a+lamivudine vs. lamivudine did not increase HBeAg seroconversion among patients with baseline HBV DNA levels >10.26 (log copies/ml)
HBeAg seroconversion | Peginterferon alfa-2a+lamivudine vs. peginterferon alfa-2a | 48/24 | 1/542 | Lau, 2005^56^ | 0.54 (0.32; 0.91) | The rates of HBeAg seroconversion were lower after peginterferon alfa-2a+lamivudine vs. peginterferon alfa-2a among the patients with baseline HBV DNA levels ≤9.07 (log copies/ml)
HBeAg seroconversion | Peginterferon alfa-2a+lamivudine vs. peginterferon alfa-2a | 48/24 | 1/542 | Lau, 2005^56^ | 1.03 (0.68; 1.54) | Random differences among patients with baseline HBV DNA levels >9.07–10.26 (log copies/ml)
1.27 (0.59; 2.75) | Random differences among patients with baseline HBV DNA levels>10.26 (log copies/ml)
Sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | Peginterferon alfa-2a+placebo vs. lamivudine | 48/24 | 1/96 | Bonino, 2007^114^ | 1.27 (0.71; 2.30) | Random differences among patients with baseline HBV DNA <6.12 log10 copies/ml
Sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | Peginterferon alfa-2a+placebo vs. lamivudine | 48/24 | 1/96 | Bonino, 2007^114^ | 3.87 (2.55; 5.88) | Peginterferon alfa-2a+ placebo vs. lamivudine increased the rates of sustained response among patients with baseline HBV DNA >6.12–8.42 log 10 copies/ml
1.80 (0.91; 3.57) | Random differences among patients with baseline HBV DNA >8.42 log 10 copies/ml
HBeAg seroconversion | Peginterferon alfa-2a+placebo vs. lamivudine | 48/24 | 1/543 | Lau, 2005^56^ | 1.55 (0.95; 2.51) | Random differences among patients with baseline HBV DNA levels ≤9.07 (log copies/ml)
HBeAg seroconversion | Peginterferon alfa-2a+placebo vs. lamivudine | 48/24 | 1/543 | Lau, 2005^56^ | 1.86 (1.13; 3.08) | Peginterferon alfa-2a+placebo vs. lamivudine increased rates of HBeAg seroconversion among patients with baseline HBV DNA levels >9.07–10.26 (log copies/ml)
1.58 (0.62; 4.01) | Random differences among patients with baseline HBV DNA levels >10.26 (log copies/ml)
Adjusted odds ratios of sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | Peginterferon alfa-2a vs. lamivudine | 48/24 | 1/1036 | Bonino, 2007^114^ | 1.06 (0.93; 1.21) | Baseline HBV DNA (Log10) was not associated with sustained response to therapy
Adjusted for treatment allocation, hepatitis B virus (HBV) genotype, baseline ALT odds ratio of persistent HBeAg loss at any time up to week 76 of post-treatment followup | Peginterferon alfa-2b+lamivudine vs. lamivudine | 60/0 | 1/100 | Chan, 2006^118^ | 0.70 (0.38; 1.30) | Baseline HBV DNA (log10) was not associated with sustained response to therapy
Adjusted for treatment allocation, HBV DNA genotype, IL-1b-511 polymorphism, baseline ALT odds ratio of persistent HBeAg loss and had less than 2 occasions with HBV DNA <100,000 copies/mL at any time up to week 76 of post-treatment | Peginterferon alfa-2b+lamivudine vs. lamivudine | 60/0 | 1/100 | Chan, 2006^118^ | 0.65 (0.35; 1.20) | Baseline HBV DNA (log10) was not associated with sustained response to therapy
Adjusted odds ratio of sustained HBeAg loss | Peginterferon alfa-2b+lamivudine vs. peginterferon alfa-2b | 52/0 | 1/307 | Janssen, 2005^78^ | 1.60 (1.30; 1.80) | Peginterferon alfa-2b+lamivudine vs. peginterferon alfa-2b increased the rates of HBeAg loss among patients with low baseline viral load
Multivariate adjusted odds ratio of sustained combined response: HBeAg negative, HBV DNA <5 log10 copies/mL, and normal ALT level | Peginterferon alfa-2b vs. interferon Alfa 2b | 24/0 | 1/230 | Zhao, 2007^81^ | 0.53 (0.22; 1.28) | Random difference among patients with baseline HBV DNA >8.1 vs. <8.1 log 10 copies/mL
Genotype, the outcomes at followup off the treatment
Adjusted for age, gender, baseline ALT, HBV DNA, and histology, precore G1896A mutation, core promoter A1762T, G1764A, and treatment with interferon with and without prednisone pretreatment odds ratios of antiviral response: as sustained clearance of serum HBV DNA | Interferon Alfa 2b+corticosteroid vs. interferon Alfa 2b | 24/0 | 1/115 | Wai, 2002^102^ | 1.28 (1.06; 1.42) | Patients with HBV genotype B vs. C had better sustained response to the therapy
1/68 | Wai, 2002^102^ | 1.47 (1.18; 1.82) | Patients with HBV genotype B vs. C and elevated baseline ALT had better sustained response to the therapy
Sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | Peginterferon alfa-2a+lamivudine vs. lamivudine | 48/24 | 1/126 | Bonino, 2007^114^ | 2.09 (1.29; 3.40) | Peginterferon alfa-2a+lamivudine vs. lamivudine increased the rates of sustained response among patients with genotype C
3.33 (1.53; 7.27) | Peginterferon alfa-2a+lamivudine vs. lamivudine increased the rates of sustained response among patients with genotype D
HBeAg seroconversion | Peginterferon alfa-2a+lamivudine vs. lamivudine | 48/24 | 1/543 | Lau, 2005^56^ | 1.34 (0.30; 5.92) | Random difference among patients with HBV genotype A
HBeAg seroconversion | Peginterferon alfa-2a+lamivudine vs. lamivudine | 48/24 | 1/543 | Lau, 2005^56^ | 1.42 (0.78; 2.58) | Random difference among patients with HBV genotype B
HBeAg seroconversion | Peginterferon alfa-2a+lamivudine vs. lamivudine | 48/24 | 1/543 | Lau, 2005^56^ | 1.49 (0.96; 2.31) | Random difference among patients with HBV genotype C
0.67 (0.11; 3.97) | Random difference among patients with HBV genotype D
HBeAg seroconversion | Peginterferon alfa-2a+lamivudine vs. peginterferon alfa-2a | 48/24 | 1/542 | Lau, 2005^56^ | 0.33 (0.11; 1.02) | Random difference among patients with HBV genotype A
HBeAg seroconversion | Peginterferon alfa-2a+lamivudine vs. peginterferon alfa-2a | 48/24 | 1/542 | Lau, 2005^56^ | 1.04 (0.60; 1.80) | Random difference among patients with HBV genotype B
HBeAg seroconversion | Peginterferon alfa-2a+lamivudine vs. peginterferon alfa-2a | 48/24 | 1/542 | Lau, 2005^56^ | 0.86 (0.59; 1.25) | Random difference among patients with HBV genotype C
1.00 (0.14; 7.05) | Random difference among patients with HBV genotype D
Sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | Peginterferon alfa-2a+placebo vs. lamivudine | 48/24 | 1/19 | Bonino, 2007^114^ | 2.18 (0.27; 17.32) | Random differences among patients with genotype A
Sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | Peginterferon alfa-2a+placebo vs. lamivudine | 48/24 | 1/19 | Bonino, 2007^114^ | 1.14 (0.70; 1.85) | Random differences among patients with genotype B
Sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | Peginterferon alfa-2a+placebo vs. lamivudine | 48/24 | 1/19 | Bonino, 2007^114^ | 2.22 (1.36; 3.63) | Peginterferon alfa-2a+placebo vs. lamivudine increased the rates of sustained response among patients with genotype C
1.47 (0.59; 3.69) | Random differences among patients with genotype D
HBeAg seroconversion | Peginterferon alfa-2a+placebo vs. lamivudine | 48/24 | 1/543 | Lau, 2005^56^ | 4.01 (1.15; 14.07) | Peginterferon alfa-2a+placebo vs. lamivudine increased the rates of HBeAg seroconversion among patients with HBV genotype A
HBeAg seroconversion | Peginterferon alfa-2a+placebo vs. lamivudine | 48/24 | 1/543 | Lau, 2005^56^ | 1.36 (0.74; 2.48) | Random differences among patients with HBV genotype B
HBeAg seroconversion | Peginterferon alfa-2a+placebo vs. lamivudine | 48/24 | 1/543 | Lau, 2005^56^ | 1.73 (1.13; 2.65) | Peginterferon alfa-2a+placebo vs. lamivudine increased the rates of HBeAg seroconversion among patients with HBV genotype C
0.67 (0.11; 3.97) | Random differences among patients with HBV genotype D
Adjusted odds ratios of sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | Peginterferon alfa-2a vs. lamivudine | 48/24 | 1/1036 | Bonino, 2007^114^ | 2.58 (0.73; 9.20) | Random difference between genotypes (A vs. D)
Adjusted odds ratios of sustained combined response: ALT normalization and an HBV DNA level of <20,000 copies/ml | Peginterferon alfa-2a vs. lamivudine | 48/24 | 1/1036 | Bonino, 2007^114^ | 3.69 (1.54; 8.79) | Rates of sustained response were higher among patients with genotype B vs. D
5.46 (2.46; 12.10) | Rates of sustained response were higher among patients with genotype C vs. D
Adjusted for treatment allocation, hepatitis B virus (HBV) genotype, baseline alanine aminotransferase and log HBV DNA odds ratio of persistent HBeAg loss at any time up to week 76 of post-treatment | Peginterferon alfa-2b+lamivudine vs. lamivudine | 60/24 | 1/100 | Chan, 2006^118^ | 10.37 (1.11; 96.96) | Rates of response were higher among patients with interleukin (IL)-1b-511 baseline genotype C/T vs. C/C
Adjusted for treatment allocation, hepatitis B virus (HBV) genotype, baseline alanine aminotransferase and log HBV DNA odds ratio of persistent HBeAg loss at any time up to week 76 of post-treatment | Peginterferon alfa-2b+lamivudine vs. lamivudine | 60/24 | 1/100 | Chan, 2006^118^ | Random differences in patients with genotype C vs. B
Adjusted for treatment allocation, hepatitis B virus (HBV) genotype, baseline alanine aminotransferase and log HBV DNA odds ratio of persistent HBeAg loss at any time up to week 76 of post-treatment | Peginterferon alfa-2b+lamivudine vs. lamivudine | 60/24 | 1/100 | Chan, 2006^118^ | Random differences in patients with Haplotype -511/-31 of interleukin (IL)-1b C-T vs. T-C
Adjusted for treatment allocation, hepatitis B virus (HBV) genotype, baseline alanine aminotransferase and log HBV DNA odds ratio of persistent HBeAg loss at any time up to week 76 of post-treatment | Peginterferon alfa-2b+lamivudine vs. lamivudine | 60/24 | 1/100 | Chan, 2006^118^ | Random differences in patients with interleukin (IL)-1b-511 baseline genotype T/T vs. C/C
Adjusted for treatment allocation, hepatitis B virus (HBV) genotype, baseline alanine aminotransferase and log HBV DNA odds ratio of persistent HBeAg loss at any time up to week 76 of post-treatment | Peginterferon alfa-2b+lamivudine vs. lamivudine | 60/24 | 1/100 | Chan, 2006^118^ | Random differences in patients with interleukin (IL)-1b-31 baseline genotype C/T vs. T/T or C/C vs. T/T
Adjusted for treatment allocation, hepatitis B virus (HBV) genotype, baseline alanine aminotransferase and log HBV DNA odds ratio of persistent HBeAg loss at any time up to week 76 of post-treatment | Peginterferon alfa-2b+lamivudine vs. lamivudine | 60/24 | 1/100 | Chan, 2006^118^ | Random differences in patients with IL-1 receptor antagonist genotype IL-1RN 1/2 vs. 1/1
Adjusted for treatment allocation, hepatitis B virus (HBV) genotype, baseline alanine aminotransferase and log HBV DNA odds ratio of persistent HBeAg loss at any time up to week 76 of post-treatment | Peginterferon alfa-2b+lamivudine vs. lamivudine | 60/24 | 1/100 | Chan, 2006^118^ | Random differences in patients with interleukin (IL)-1b-511 baseline genotype C/T and T/T vs. C/C
Random differences in patients with interleukin (IL)-1b-31 baseline genotype C/T and C/C vs. T/T
Adjusted relative risk of HBeAg seroconversion and HBV DNA 10,000 copies/ml. | Peginterferon alfa-2b+lamivudine vs. peginterferon alfa-2b | 52/26 | 1/307 | Buster, 2007^124^ | 11.30 (1.38; 92.57) | adjusted rates of sustained response were higher among patients with genotype A vs. C
Adjusted relative risk of HBeAg seroconversion and HBV DNA 10,000 copies/ml. | Peginterferon alfa-2b+lamivudine vs. peginterferon alfa-2b | 52/26 | 1/307 | Buster, 2007^124^ | 4.28 (1.39; 13.21) | Adjusted rates of sustained response were higher among patients with genotype A vs. D
Adjusted relative risk of HBeAg seroconversion and HBV DNA 10,000 copies/ml. | Peginterferon alfa-2b+lamivudine vs. peginterferon alfa-2b | 52/26 | 1/307 | Buster, 2007^124^ | 12.13 (1.24; 118.30) | Adjusted rates of sustained response were higher among patients with genotype B vs. C
4.59 (1.14; 18.43) | Adjusted rates of sustained response were higher among patients with genotype B vs. D
Adjusted odds ratio of sustained HBeAg loss | Peginterferon alfa-2b+lamivudine vs. peginterferon alfa-2b | 52/26 | 1/307 | Janssen, 2005^78^ | 2.40 (1.30; 4.60) | Adjusted rates of sustained response were higher among patients with HBV genotype A vs. D
Adjusted odds ratio of sustained HBeAg loss | Peginterferon alfa-2b+lamivudine vs. peginterferon alfa-2b | 52/26 | 1/307 | Janssen, 2005^78^ | 3.60 (1.40; 8.90) | Adjusted rates of sustained response were higher among patients with HBV genotype A vs. C
2.20 (0.70; 7.00) | Random difference among patients with HBV genotype B vs. C
Multivariate adjusted odds ratio of sustained combined response: HBeAg negative, HBV DNA <5 log 10 copies/mL, and normal ALT level | Peginterferon alfa-2b vs. interferon Alfa 2b | 24/24 | 0/250 | Zhao, 2007^81^ | 0.19 (0.08; 0.46) | RR, genotype C vs. B
Previous treatment, outcomes at followup off the treatment
HBeAg seroconversion | Peginterferon alfa-2a+lamivudine vs. lamivudine | 48/24 | 1/543 | Lau, 2005^56^ | 1.52 (1.08; 2.12) | Rates of HBeAg seroconversion were higher among patients with no previous exposure to lamivudine
Random differences among those with previous LAM or Interferon therapy
HBeAg seroconversion | Peginterferon alfa-2a + lamivudine vs. peginterferon alfa-2a | 48/24 | 1/542 | Lau, 2005^56^ | Random differences among all patients with and without previous treatment
HBeAg seroconversion | Peginterferon alfa-2a+placebo vs. lamivudine | 48/24 | 1/543 | Lau, 2005^56^ | 1.58 (1.11; 2.23) | peginterferon alfa-2a+placebo vs. lamivudine increased the rates of HBeAg seroconversion among patients with no previous anti-HBV therapy
HBeAg seroconversion | Peginterferon alfa-2a+placebo vs. lamivudine | 48/24 | 1/543 | Lau, 2005^56^ | 1.43 (0.55; 3.71) | Random differences among patients with previous treatment: LAM
HBeAg seroconversion | Peginterferon alfa-2a+placebo vs. lamivudine | 48/24 | 1/543 | Lau, 2005^56^ | 1.72 (1.24; 2.38) | Peginterferon alfa-2a+placebo vs. lamivudine increased the rates of HBeAg seroconversion among patients with no previous exposure to lamivudine
HBeAg seroconversion | Peginterferon alfa-2a+placebo vs. lamivudine | 48/24 | 1/543 | Lau, 2005^56^ | 3.26 (1.08; 9.88) | Peginterferon alfa-2a+placebo vs. lamivudine increased the rates of HBeAg seroconversion among patients with previous treatment: IFN
1.55 (1.12; 2.14) | Peginterferon alfa-2a+placebo vs. lamivudine increased the rates of HBeAg seroconversion among patients with no previous exposure to conventional interferon
HBeAg loss | Peginterferon alfa-2b+lamivudine vs. peginterferon alfa-2b | 52/26 | 2/307 | Janssen, 2005^78^ | 2.20 (1.10; 4.50) | Peginterferon alfa-2b+lamivudine vs. peginterferon alfa-2b increased the rates of HBeAg loss among patients without previous interferon therapy
HBeAg loss | Peginterferon alfa-2b+lamivudine vs. peginterferon alfa-2b | 52/26 | Flink, 2006^121^ | 0.94 (0.63; 1.40) | Random differences among naïve to any treatments patients
1/307 | Flink, 2006^121^ | Random differences among patients with previous IFN, LAM, and combined therapy
HBV DNA loss, normalization of ALT | | | | | Random differences among patients naïve to any antiviral treatment

Table E11 Rates of clinical, intermediate, and adverse outcomes after antiviral treatment / no treatment by baseline HBeAg status at the end of treatment and at followup off treatment. (results from individual RCTs and pooled analyses with random effects models. Rates pooled from RCTs that reported outcomes independent of active or control regime)

Antiviral Treatment | Studies | Outcome Assessment | Outcome | 95% CI
HBeAg-negative patients
Entecavir ^74^ | 1 | End | Flare | 1.00 (0.98;1.02)
Entecavir ^74^
Entecavir ^74^ | 1 | End | Death | 1.00 (0.98;1.02)
Entecavir ^74^
Entecavir ^74^ | 1 | End | Relapse | 1.99 (1.96;2.03)
Entecavir ^74^
Entecavir ^74^ | 1 | End | Resistance | 17.99 (17.30;18.71)
Entecavir ^74^
Entecavir ^74^ | 1 | End | Improved histology | 64.07 (60.41;67.95)
Entecavir ^74^
Entecavir ^74^ | 1 | End | Normalization ALT | 78.26 (75.25;81.39)
1 | End | HBV DNA loss | 90.02 (86.56;93.62)
1 | Followup off treatment | Flare | 7.03 (6.89;7.17)
1 | | Any adverse event | 75.94 (73.03;78.98)
1 | | Serious adverse event | 5.99 (5.87;6.11)
1 | | Discontinuation due to adverse event | 2.00 (1.98;2.02)
1 | | ALT >2× baseline and >5× ULN | 4.69 (0.88;25.05)
Adefovir dipivoxil ^41,^,^97,98^
Adefovir dipivoxil ^41,^,^97,98^
Adefovir dipivoxil ^41,^,^97,98^ | 1 | End | Death | 0.63 (0.26;1.56)
Adefovir dipivoxil ^41,^,^97,98^
Adefovir dipivoxil ^41,^,^97,98^ | 1 | End | Failure | 3.47 (2.61;4.61)
Adefovir dipivoxil ^41,^,^97,98^
Adefovir dipivoxil ^41,^,^97,98^ | 2 | End | HBsAg seroconversion | 1.36 (0.76;2.45)
Adefovir dipivoxil ^41,^,^97,98^
Adefovir dipivoxil ^41,^,^97,98^ | 3 | End | HBV DNA loss | 62.84 (57.20;69.03)
Adefovir dipivoxil ^41,^,^97,98^
Adefovir dipivoxil ^41,^,^97,98^ | 1 | End | HCC | 2.00 (0.51;7.82)
Adefovir dipivoxil ^41,^,^97,98^
Adefovir dipivoxil ^41,^,^97,98^ | 3 | End | Improved histology | 36.43 (24.62;53.90)
Adefovir dipivoxil ^41,^,^97,98^
Adefovir dipivoxil ^41,^,^97,98^ | 3 | End | Mutation | 3.93 (1.59;9.71)
Adefovir dipivoxil ^41,^,^97,98^
Adefovir dipivoxil ^41,^,^97,98^ | 3 | End | Normalization ALT | 65.83 (62.72;69.09)
Adefovir dipivoxil ^41,^,^97,98^
Adefovir dipivoxil ^41,^,^97,98^ | 2 | End | Resistance | 7.33 (4.02;13.37)
Adefovir dipivoxil ^41,^,^97,98^
Adefovir dipivoxil ^41,^,^97,98^ | 1 | End | HBsAg loss | 1.41 (0.12;16.85)
Adefovir dipivoxil ^41,^,^97,98^
Adefovir dipivoxil ^41,^,^97,98^ | 1 | Followup off treatment | HBV DNA loss | 66.02 (61.60;70.76)
Adefovir dipivoxil ^41,^,^97,98^
Adefovir dipivoxil ^41,^,^97,98^ | 1 | Followup off treatment | Improved histology | 70.81 (65.47;76.59)
Adefovir dipivoxil ^41,^,^97,98^
Adefovir dipivoxil ^41,^,^97,98^ | 1 | Followup off treatment | Mutation | 4.48 (3.96;5.08)
Adefovir dipivoxil ^41,^,^97,98^
Adefovir dipivoxil ^41,^,^97,98^ | 1 | Followup off treatment | Normalization ALT | 54.06 (50.44;57.93)
Adefovir dipivoxil ^41,^,^97,98^
Adefovir dipivoxil ^41,^,^97,98^ | 1 | | Any adverse events | 70.31 (59.85;82.59)
Adefovir dipivoxil ^41,^,^97,98^
Adefovir dipivoxil ^41,^,^97,98^ | 3 | | Headache | 14.94 (11.10;20.12)
Adefovir dipivoxil ^41,^,^97,98^
Adefovir dipivoxil ^41,^,^97,98^ | 3 | | Abdominal pain | 15.38 (11.44;20.68)
Adefovir dipivoxil ^41,^,^97,98^
Adefovir dipivoxil ^41,^,^97,98^ | 3 | | Asthenia | 10.09 (7.32;13.91)
Adefovir dipivoxil ^41,^,^97,98^
Adefovir dipivoxil ^41,^,^97,98^ | 2 | | Flu-like syndrome | 11.10 (8.64;14.25)
3 | | Back pain | 7.25 (5.65;9.29)
3 | | Pain | 8.65 (6.72;11.13)
2 | | Accidental injury | 5.53 (4.01;7.62)
1 | | Diarrhea | 4.41 (2.56;7.61)
3 | | Dyspepsia | 4.66 (3.20;6.78)
3 | | Pharyngitis | 19.20 (15.82;23.31)
2 | | Increased cough | 4.81 (3.49;6.62)
2 | | Bronchitis | 4.20 (2.48;7.09)
1 | | Increased ALT | 2.44 (1.89;3.14)
1 | | Arthralgia | 4.41 (2.56;7.61)
1 | | Increased creatinine PK | 1.68 (1.06;2.66)
1 | | Hematuria | 1.64 (1.24;2.17)
1 | | Kidney calculus | 1.18 (0.85;1.63)
1 | | Kidney pain | 1.86 (0.96;3.62)
1 | | Infection | 2.52 (0.07;93.79)
1 | | Cough increased | 8.12 (4.47;14.77)
2 | | Rhinitis | 2.71 (0.32;22.88)
1 | | At least one adverse event | 75.94 (70.22;82.14)
1 | | Serious adverse event | 3.00 (2.89;3.12)
1 | | Insomnia | 5.00 (4.81;5.20)
Interferon alfa-2b ^84,88^ | 2 | End | Combined | 34.78 (27.52;43.95)
Interferon alfa-2b ^84,88^
Interferon alfa-2b ^84,88^ | 1 | End | HBsAg loss | 2.39 (2.25;2.53)
Interferon alfa-2b ^84,88^
Interferon alfa-2b ^84,88^ | 1 | End | Flare | 18.92 (16.17;22.13)
Interferon alfa-2b ^84,88^
Interferon alfa-2b ^84,88^ | 1 | End | Improved histology | 33.12 (27.76;39.50)
Interferon alfa-2b ^84,88^
Interferon alfa-2b ^84,88^ | 1 | End | Resistance | 8.32 (0.72;96.40)
Interferon alfa-2b ^84,88^
Interferon alfa-2b ^84,88^ | 2 | Followup off treatment | Combined | 26.96 (17.71;41.05)
Interferon alfa-2b ^84,88^
2 | Followup off treatment | Relapse | 12.60 (7.95;19.97)
1 | Followup off treatment | HBsAg loss | 9.97 (8.87;11.22)
1 | Followup off treatment | HBsAg seroconversion | 9.97 (8.87;11.22)
1 | | Discontinuation due to adverse effects | 24.05 (20.16;28.69)
1 | | Persistent headache | 5.00 (4.63;5.41)
1 | | Persistent Myalgia | 14.01 (12.22;16.07)
1 | | Moderate depression | 5.00 (4.63;5.41)
Interferon alfa-2b+Lamivudine ^60,62^–^64^ | 2 | End | HBV DNA loss | 96.03 (92.45;99.76)*
Interferon alfa-2b+Lamivudine ^60,62^–^64^
Interferon alfa-2b+Lamivudine ^60,62^–^64^ | 3 | End | Relapse | 6.87 (2.84;16.61)
Interferon alfa-2b+Lamivudine ^60,62^–^64^
Interferon alfa-2b+Lamivudine ^60,62^–^64^ | 2 | End | Normalization ALT | 68.05 (51.22;90.40)
Interferon alfa-2b+Lamivudine ^60,62^–^64^
Interferon alfa-2b+Lamivudine ^60,62^–^64^ | 2 | End | Flare | 5.10 (1.92;13.57)
Interferon alfa-2b+Lamivudine ^60,62^–^64^
Interferon alfa-2b+Lamivudine ^60,62^–^64^ | 3 | End | Mutation | 2.19 (1.65;2.91)
Interferon alfa-2b+Lamivudine ^60,62^–^64^
Interferon alfa-2b+Lamivudine ^60,62^–^64^ | 1 | End | HBsAg loss | 1.25 (1.20;1.30)
Interferon alfa-2b+Lamivudine ^60,62^–^64^
Interferon alfa-2b+Lamivudine ^60,62^–^64^ | 2 | End | Combined | 64.87 (42.58;98.85)
Interferon alfa-2b+Lamivudine ^60,62^–^64^
1 | Followup off treatment | HBV DNA loss | 20.91 (17.87;24.45)
2 | Followup off treatment | Normalization ALT | 36.48 (17.50;76.08)
2 | Followup off treatment | HBsAg loss | 1.27 (0.49;3.32)
1 | Followup off treatment | Combined | 18.92 (16.17;22.13)
1 | | Serious adverse events including pyrexia, fatigue, myalgia and headache | 9.03 (8.51;9.57)
2 | | Discontinuation due to adverse events | 12.88 (11.02;15.07)
1 | | Thrombocytopenia | 27.94 (24.36;32.05)
1 | | Dose reduction due to adverse effects | 9.97 (9.04;11.00)
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^ | 5 | End | Normalization ALT | 68.33 (63.19;73.89)
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^ | 4 | End | Combined | 36.27 (4.21;312.53)
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^ | 4 | End | HBV DNA loss | 53.96 (31.34;92.89)
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^ | 4 | End | Relapse | 15.07 (9.59;23.68)
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^ | 3 | End | Flare | 4.93 (2.76;8.79)
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^ | 3 | End | Mutation | 14.75 (5.08;42.82)
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^ | 1 | End | HBsAg loss | 1.25 (1.20;1.30)
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^ | 2 | End | Improved histology | 18.48 (5.04;67.72)
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^ | 2 | End | Resistance | 20.84 (15.69;27.70)
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^ | 1 | End | Death | 0.16 (0.16;0.16)
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^ | 1 | End | Failure | 1.41 (0.72;2.78)
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^ | 4 | Followup off treatment | Combined | 14.61 (9.07;23.55)
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^ | 1 | Followup off treatment | Failure | 5.99 (3.08;11.65)
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^ | 1 | Followup off treatment | Flare | 9.03 (8.68;9.39)
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^ | 2 | Followup off treatment | HBV DNA loss | 10.83 (9.09;12.91)
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^ | 1 | Followup off treatment | Improved histology | 24.52 (15.31;39.25)
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^ | 1 | Followup off treatment | Normalization ALT | 38.23 (28.66;50.99)
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^ | 3 | Followup off treatment | HBsAg loss | 0.99 (0.54;1.81)
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^ | 1 | | >1 Reported adverse event | 48.00 (47.95;48.05) †
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^ | 1 | | >1 Reported serious AE | 3.00 (2.99;3.01) †
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^ | 1 | | Abdominal discomfort | 8.50 (5.56;11.44) †
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^ | 1 | | Alopecia | 1.00 (0.99;1.01) †
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^ | 1 | | ALT >2× baseline | 12.00 (11.23;12.82)
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^ | 1 | | Any adverse event | 79.00 (78.96;79.04) †
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^ | 1 | | Arthralgia | 3.00 (2.99;3.01) †
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^ | 1 | | At least 1 adverse event | 50.00 (44.12;55.88) †
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^ | 1 | | Back pain | 3.00 (2.99;3.01) †
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^ | 2 | | Cough | 4.25 (2.93;5.57) †
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^ | 1 | | Death | 0.28 (0.28;0.28) †
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^ | 1 | | Decreased appetite | 3.00 (2.99;3.01) †
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^ | 2 | | Diarrhea | 4.00 (3.14;4.86) †
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^ | 1 | | Discontinuation due to adverse effects | 1.92 (1.87;1.97) †
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^ | 1 | | Discontinuation for safety reasons | 0.28 (0.27;0.28) †
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^ | 1 | | Dizziness | 4.00 (3.97;4.03) †
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^ | 1 | | Dose modification | 0.28 (0.27;0.28) †
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^ | 1 | | Dose modification due to adverse event | 0.28 (0.27;0.28) †
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^ | 1 | | Dose modification due to Laboratory abnormality | 0.28 (0.27;0.28) †
Lamivudine ^46,^,^49,^,^57,^,^60,62^–^64,^,^74,114^
1 | | Dose modification due to Alanine aminotransferase elevation | 0.28 (0.27;0.28) †
1 | | Dose modification due to Neutropenia | 0.28 (0.27;0.28) †
1 | | Dose modification due to thrombocytopenia | 0.28 (0.27;0.28) †
1 | | Dose reduction | 1.25 (1.22;1.28) †
1 | | Dyspepsia | 9.00 (8.94;9.06) †
1 | | Dyspeptic symptoms | 4.00 (2.04;5.96) †
1 | | Fatigue | 18.00 (17.96;18.04) †
1 | | Gastrointestinal infection | 5.00 (4.97;5.04) †
3 | | Headache | 11.60 (8.38;14.82) †
1 | | Insomnia | 3.00 (2.99;3.01) †
1 | | Irritability | 2.00 (1.99;2.01) †
1 | | Malaise and fatigue | 15.50 (10.60;20.40) †
1 | | Musculoskeletal pain | 3.00 (2.97;3.03) †
1 | | Myalgia | 6.00 (5.98;6.02) †
1 | | Nausea | 5.00 (4.98;5.02) †
1 | | Nausea and vomiting | 8.00 (7.95;8.05) †
1 | | Pruritus | 2.00 (1.99;2.01) †
1 | | Pyrexia | 4.00 (3.98;4.02) †
1 | | Rigors | 0.28 (0.28;0.28) †
1 | | Sore throat | 4.00 (3.98;4.02) †
2 | | Thrombocytopenia | 8.00 (7.95;8.05) †
1 | | Tonsillitis | 7.00 (6.58;7.45)
1 | | Upper abdominal pain | 8.00 (7.97;8.03) †
1 | | Upper respiratory tract infection | 4.00 (3.98;4.02) †
1 | | URTI symptoms | 33.00 (32.90;33.10) †
1 | | Viral respiratory infection | 6.00 (4.04;7.96) †
1 | | Increased ALP | 10.00 (9.94;10.06) †
1 | | Increased ALT | 12.00 (11.93;12.07) †
1 | | Increased amylase | 3.00 (2.97;3.03) †
1 | | Increased bilirubin | 1.00 (0.98;1.02) †
1 | | Increased CPK | 3.00 (2.97;3.03) †
1 | | Low neutrophil count | 0.56 (0.55;0.58) †
1 | | Serious adverse event | 8.00 (7.97;8.03) †
1 | | Serious adverse events including pyrexia, fatigue, myalgia and headache | 0.51 (0.50;0.52) †
1 | | Right upper quadrant discomfort | 17.00 (16.92;17.08) †
1 | | Prolonged PT level | 1.00 (0.98;1.02) †
1 | | Temperature regulation disturbance | 8.00 (7.93;8.07) †
1 | | Vertigo | 2.50 (1.52;3.48) †
Peginterferon alfa-2a ^57,114^ | 1 | End | Combined | 30.23 (22.53;40.56)
Peginterferon alfa-2a ^57,114^
Peginterferon alfa-2a ^57,114^ | 1 | End | Normalization ALT | 36.97 (34.18;39.98)
Peginterferon alfa-2a ^57,114^
Peginterferon alfa-2a ^57,114^ | 2 | Followup off treatment | Combined | 21.03 (12.94;34.18)
Peginterferon alfa-2a ^57,114^
Peginterferon alfa-2a ^57,114^ | 1 | Followup off treatment | Normalization ALT | 57.97 (53.60;62.70)
Peginterferon alfa-2a ^57,114^
Peginterferon alfa-2a ^57,114^ | 1 | Followup off treatment | Improved histology | 29.07 (10.61;79.62)
Peginterferon alfa-2a ^57,114^
Peginterferon alfa-2a ^57,114^ | 1 | End | Failure | 7.35 (4.92;10.99)
Peginterferon alfa-2a ^57,114^
Peginterferon alfa-2a ^57,114^ | 1 | End | ≥1 Reported adverse event | 86.00 (85.95;86.05)
Peginterferon alfa-2a ^57,114^
Peginterferon alfa-2a ^57,114^ | 1 | End | ≥1 Reported serious adverse event | 5.00 (4.97;5.03)
Peginterferon alfa-2a ^57,114^
Peginterferon alfa-2a ^57,114^ | 1 | End | Alopecia | 13.00 (12.95;13.05)
Peginterferon alfa-2a ^57,114^
Peginterferon alfa-2a ^57,114^ | 1 | End | Arthralgia | 15.00 (14.95;15.05)
Peginterferon alfa-2a ^57,114^
Peginterferon alfa-2a ^57,114^ | 1 | End | Back pain | 2.00 (1.98;2.02)
Peginterferon alfa-2a ^57,114^
Peginterferon alfa-2a ^57,114^ | 1 | End | Cough | 6.00 (5.97;6.03)
Peginterferon alfa-2a ^57,114^
Peginterferon alfa-2a ^57,114^ | 1 | End | Death | 1.00 (0.99;1.01)
Peginterferon alfa-2a ^57,114^
Peginterferon alfa-2a ^57,114^ | 1 | End | Decreased appetite | 17.00 (16.95;17.05)
Peginterferon alfa-2a ^57,114^
Peginterferon alfa-2a ^57,114^ | 1 | End | Diarrhea | 11.00 (10.95;11.05)
Peginterferon alfa-2a ^57,114^
Peginterferon alfa-2a ^57,114^ | 1 | End | Discontinuation for other reasons | 1.00 (0.99;1.01)
Peginterferon alfa-2a ^57,114^
Peginterferon alfa-2a ^57,114^ | 1 | End | Discontinuation for safety reasons | 7.00 (6.96;7.04)
Peginterferon alfa-2a ^57,114^
Peginterferon alfa-2a ^57,114^ | 1 | End | Dizziness | 8.00 (7.96;8.04)
Peginterferon alfa-2a ^57,114^
1 | End | Dose modification | 46.00 (45.93;46.07)
1 | End | Dose modification due to adverse event | 7.00 (6.96;7.04)
1 | End | Dose modification due to Alanine aminotransferase elevation | 8.00 (7.96;8.04)
1 | End | Dose modification due to Laboratory abnormality | 36.00 (35.93;36.07)
1 | End | Dose modification due to Neutropenia | 17.00 (16.95;17.05)
1 | End | Dose modification due to thrombocytopenia | 19.00 (18.94;19.06)
1 | End | Fatigue | 41.00 (40.93;41.07)
1 | End | Headache | 23.00 (22.94;23.06)
1 | End | Injection-site reaction | 6.00 (5.97;6.03)
1 | End | Insomnia | 8.00 (7.96;8.04)
1 | End | Irritability | 7.00 (6.96;7.04)
1 | End | Myalgia | 26.00 (25.94;26.06)
1 | End | Nausea | 8.00 (7.96;8.04)
1 | End | Pruritus | 5.00 (4.97;5.03)
1 | End | Pyrexia | 58.00 (57.93;58.07)
1 | End | Rigors | 6.00 (5.97;6.03)
1 | End | Sore throat | 6.00 (5.97;6.03)
1 | End | Upper abdominal pain | 5.00 (4.97;5.03)
1 | End | Upper respiratory tract infection | 5.00 (4.97;5.03)
Peginterferon alfa-2a+Lamivudine ^57^ | 1 | End | Normalization ALT | 47.94 (44.33;51.85)
Peginterferon alfa-2a+Lamivudine ^57^
Peginterferon alfa-2a+Lamivudine ^57^ | 1 | End | Combined | 46.53 (43.87;49.34)
Peginterferon alfa-2a+Lamivudine ^57^
Peginterferon alfa-2a+Lamivudine ^57^ | 1 | Followup off treatment | Normalization ALT | 59.15 (54.69;63.97)
Peginterferon alfa-2a+Lamivudine ^57^
Peginterferon alfa-2a+Lamivudine ^57^ | 1 | Followup off treatment | Combined | 24.65 (10.51;57.81)
Peginterferon alfa-2a+Lamivudine ^57^
Peginterferon alfa-2a+Lamivudine ^57^ | 1 | Followup off treatment | Improved histology | 23.88 (8.88;64.17)
Peginterferon alfa-2a+Lamivudine ^57^
Peginterferon alfa-2a+Lamivudine ^57^ | 1 | Followup off treatment | Failure | 10.18 (6.36;16.29)
Peginterferon alfa-2a+Lamivudine ^57^
Peginterferon alfa-2a+Lamivudine ^57^ | 1 | End | Death | 0.28 (0.27;0.28)
Peginterferon alfa-2a+Lamivudine ^57^
Peginterferon alfa-2a+Lamivudine ^57^ | 1 | End | Discontinuation for other reasons | 2.00 (1.98;2.02)
Peginterferon alfa-2a+Lamivudine ^57^
Peginterferon alfa-2a+Lamivudine ^57^ | 1 | End | Upper respiratory tract infection | 2.00 (1.98;2.02)
Peginterferon alfa-2a+Lamivudine ^57^
Peginterferon alfa-2a+Lamivudine ^57^ | 1 | End | Dose modification due to Alanine aminotransferase elevation | 3.00 (2.98;3.02)
Peginterferon alfa-2a+Lamivudine ^57^
Peginterferon alfa-2a+Lamivudine ^57^ | 1 | End | Sore throat | 3.00 (2.98;3.02)
Peginterferon alfa-2a+Lamivudine ^57^
Peginterferon alfa-2a+Lamivudine ^57^ | 1 | End | Rigors | 3.00 (2.98;3.02)
Peginterferon alfa-2a+Lamivudine ^57^
Peginterferon alfa-2a+Lamivudine ^57^ | 1 | End | Cough | 3.00 (2.98;3.02)
Peginterferon alfa-2a+Lamivudine ^57^
Peginterferon alfa-2a+Lamivudine ^57^ | 1 | End | Discontinuation for safety reasons | 4.00 (3.97;4.03)
Peginterferon alfa-2a+Lamivudine ^57^
Peginterferon alfa-2a+Lamivudine ^57^ | 1 | End | Irritability | 4.00 (3.97;4.03)
Peginterferon alfa-2a+Lamivudine ^57^
Peginterferon alfa-2a+Lamivudine ^57^ | 1 | End | Diarrhea | 6.00 (5.97;6.03)
Peginterferon alfa-2a+Lamivudine ^57^
Peginterferon alfa-2a+Lamivudine ^57^ | 1 | End | Pruritus | 6.00 (5.97;6.03)
Peginterferon alfa-2a+Lamivudine ^57^
Peginterferon alfa-2a+Lamivudine ^57^ | 1 | End | Back pain | 6.00 (5.97;6.03)
Peginterferon alfa-2a+Lamivudine ^57^
Peginterferon alfa-2a+Lamivudine ^57^ | 1 | End | ≥1 Reported serious adverse event | 7.00 (6.96;7.04)
Peginterferon alfa-2a+Lamivudine ^57^
Peginterferon alfa-2a+Lamivudine ^57^ | 1 | End | Dizziness | 7.00 (6.96;7.04)
Peginterferon alfa-2a+Lamivudine ^57^
1 | End | Nausea | 7.00 (6.96;7.04)
1 | End | Upper abdominal pain | 7.00 (6.96;7.04)
1 | End | Insomnia | 8.00 (7.96;8.04)
1 | End | Alopecia | 11.00 (10.95;11.05)
1 | End | Dose modification due to thrombocytopenia | 12.00 (11.95;12.05)
1 | End | Injection-site reaction | 12.00 (11.95;12.05)
1 | End | Dose modification due to adverse event | 13.00 (12.95;13.05)
1 | End | Decreased appetite | 14.00 (13.95;14.05)
1 | End | Arthralgia | 15.00 (14.95;15.05)
1 | End | Headache | 19.00 (18.94;19.06)
1 | End | Dose modification due to Neutropenia | 24.00 (23.94;24.06)
1 | End | Myalgia | 27.00 (26.94;27.06)
1 | End | Dose modification due to Laboratory abnormality | 35.00 (34.93;35.07)
1 | End | Fatigue | 41.00 (40.93;41.07)
1 | End | Dose modification | 48.00 (47.93;48.07)
1 | End | Pyrexia | 54.00 (53.93;54.07)
1 | End | ≥1 Reported adverse event | 86.00 (85.95;86.05)
1 | End | Normalization of Alanine aminotransferase and HBV DNA <400 copies/ml | 16.00 (15.95;16.05)
1 | End | Normalization of Alanine aminotransferase and HBV DNA <20,000 copies/ml | 38.00 (37.93;38.07)
1 | End | Normalization of Alanine aminotransferase and HBV DNA <400 copies/ml | 45.00 (44.93;45.07)
1 | End | Normalization of Alanine aminotransferase and HBV DNA <20,000 copies/ml | 48.00 (47.93;48.07)
Placebo or no treatment ^46,^,^49,^,^84,^,^88,^,^98,99^ | 3 | All | Improved histology | 10.40 (3.35;32.34)
Placebo or no treatment ^46,^,^49,^,^84,^,^88,^,^98,99^
Placebo or no treatment ^46,^,^49,^,^84,^,^88,^,^98,99^ | 4 | All | HBV DNA loss | 5.06 (2.04;12.55)
Placebo or no treatment ^46,^,^49,^,^84,^,^88,^,^98,99^
Placebo or no treatment ^46,^,^49,^,^84,^,^88,^,^98,99^ | 3 | All | Normalization ALT | 31.70 (28.73;34.99)
Placebo or no treatment ^46,^,^49,^,^84,^,^88,^,^98,99^
Placebo or no treatment ^46,^,^49,^,^84,^,^88,^,^98,99^ | 2 | All | Mutation | 1.98 (0.92;4.25)
Placebo or no treatment ^46,^,^49,^,^84,^,^88,^,^98,99^
Placebo or no treatment ^46,^,^49,^,^84,^,^88,^,^98,99^ | 2 | All | HBsAg seroconversion | 1.55 (1.08;2.21)
Placebo or no treatment ^46,^,^49,^,^84,^,^88,^,^98,99^
Placebo or no treatment ^46,^,^49,^,^84,^,^88,^,^98,99^ | 4 | All | Combined | 6.41 (3.52;11.65)
3 | All | HBsAg loss | 1.86 (1.17;2.98)
2 | All | Relapse | 8.91 (7.19;11.06)
1 | All | HCC | 2.39 (2.25;2.53)
1 | All | Flare | 70.81 (59.36;84.47)
4 | All | Resistance | 16.40 (5.10;52.75)
2 | All | Failure | 12.32 (3.11;48.81)
HBeAg-positive patients
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 4 | End | HBV DNA loss | 24.83 (15.74;39.18)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 4 | End | Normalization ALT | 59.46 (52.08;67.89)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 2 | End | Flare | 2.72 (0.96;7.71)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 4 | End | HBeAg loss | 16.53 (12.33;22.16)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 4 | End | HBeAg seroconversion | 12.35 (10.03;15.20)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 2 | End | Relapse | 8.97 (5.76;13.98)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 1 | End | HBsAg loss | 2.64 (2.49;2.80)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 1 | End | Improved histology | 51.72 (45.88;58.30)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 2 | End | Resistance | 21.64 (16.35;28.64)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 1 | End | Failure | 10.07 (8.85;11.47)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 1 | End | Mutation | 27.94 (26.86;29.06)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 1 | Followup off treatment | Normalization ALT | 38.86 (36.64;41.22)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 1 | | Insomnia | 20.91 (18.71;23.36)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 1 | | Discontinuation | 7.50 (6.97;8.07)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 1 | | Discontinuation due to adverse effects | 1.00 (0.99;1.01)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 1 | | Dose reduced due to an adverse event or abnormal laboratory result | 8.49 (3.83;18.83)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 2 | | Fatigue | 3.31 (2.12;5.15)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 1 | | Flu-like syndrome | 16.95 (15.83;18.14)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 1 | | Hematuria10–100 RBCs | 13.65 (10.84;17.19)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 2 | | Pharyngitis | 30.21 (25.01;36.48)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 1 | | Proteinuria mg/dL100–1000 | 8.80 (5.82;13.29)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 1 | | Rash | 20.91 (18.71;23.36)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 1 | | Sinusitis | 15.96 (14.28;17.83)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 1 | | Any adverse event | 95.00 (94.94;95.06) †
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 2 | | Asthenia | 29.84 (26.48;33.62)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 1 | | Fever | 15.96 (14.28;17.83)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 3 | | Headache | 17.27 (12.27;24.29)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 1 | | Hematuria>100 RBCs | 8.46 (5.72;12.50)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 2 | | Nasopharyngitis | 5.75 (4.98;6.63)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 1 | | Reactivation of hepatitis | 1.00 (0.99;1.01)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 1 | | Serum Glucose Grade 3 abnormalities | 11.02 (10.00;12.15)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 1 | | Total adverse effect | 63.75 (59.53;68.28)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 2 | | Upper respiratory tract infection | 9.71 (8.67;10.88)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 1 | | Incidence of elevation of serum ALT to >5 times the ULN | 28.19 (20.26;39.23)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 1 | | Increases from baseline of 0.5 mg per deciliter (44 μmol per liter) or greater in the serum creatinine level | 8.00 (7.70;8.32)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 1 | | Hypophosphatemia mg/dL (<1.0) | 1.00 (0.99;1.01)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 1 | | Hypophosphatemia mg/dL (1.0–1.5) | 1.73 (0.93;3.23)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 1 | | Bacterial infection | 2.64 (2.53;2.75)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 1 | | ALT Grade 4 >10 times the ULN) | 2.64 (2.53;2.75)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 1 | | Grade 4 (>10 times the ULN) | 2.64 (2.53;2.75)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 1 | | Amylase Grade 3 (>2–5 times the ULN) | 2.64 (2.53;2.75)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
1 | | Grade4 (>5 times the ULN) | 2.64 (2.53;2.75)
1 | | Grade4 (>30 mg/dL; <500 mg/dL) | 2.63 (2.57;2.70)
1 | | Grade4 (4+) | 2.64 (2.53;2.75)
1 | | Cough | 3.79 (2.02;7.12)
2 | | Dizziness | 4.73 (2.29;9.80)
1 | | Malaise | 2.12 (1.30;3.45)
1 | | Epigastric discomfort | 1.49 (1.13;1.97)
1 | | Gastritis | 1.10 (1.08;1.12)
1 | | Myalgia | 2.12 (1.30;3.45)
1 | | Hordeolum | 1.10 (1.08;1.12)
3 | | Abdominal pain | 7.08 (3.35;14.95)
1 | | Hepatic steatosis | 1.47 (1.09;1.97)
1 | | Toothache | 1.47 (1.09;1.97)
1 | | Allergic rhinitis | 2.33 (1.30;4.18)
1 | | Creatinine mg/dL (1.5–2.0) | 2.51 (1.11;5.68)
1 | | Glycosuria (+1) | 1.41 (0.96;2.09)
1 | | Glycosuria (+2) | 1.41 (0.96;2.09)
1 | | Glycosuria (+3) | 1.00 (0.99;1.01)
1 | | Discontinuation due to adverse events | 2.45 (1.94;3.09)
3 | | Diarrhea | 7.24 (3.97;13.22)
3 | | Nausea | 7.22 (4.15;12.57)
1 | | Pharyngolaryngeal pain | 3.74 (2.04;6.87)
1 | | Mouth ulceration | 3.16 (1.93;5.17)
1 | | Anorexia | 6.33 (4.08;9.81)
1 | | Hypophosphatemia mg/dL (2.0–2.2) | 5.55 (4.16;7.40)
2 | | Arthralgia | 6.00 (4.69;7.67)
1 | | Gastroenteritis | 5.00 (4.67;5.36)
1 | | Infection | 5.00 (4.67;5.36)
1 | | Rhinitis | 5.00 (4.67;5.36)
1 | | AST Grade3 (>5–10 times the ULN) | 5.00 (4.67;5.36)
1 | | Upper abdominal pain | 7.42 (4.80;11.46)
3 | | Back pain | 7.96 (6.78;9.36)
2 | | Increased cough | 8.97 (6.78;11.87)
1 | | Influenza | 7.97 (6.91;9.18)
2 | | Pain | 9.86 (8.50;11.44)
1 | | Flatulence | 8.94 (7.89;10.12)
1 | | Severe (grade 3 or 4) clinical adverse events | 9.49 (8.97;10.04)
1 | | Dyspepsia | 9.97 (8.91;11.17)
1 | | Urine Glucose Grade3 | 11.02 (10.00;12.15)
1 | | Hematuria>100 RBCs | 12.37 (11.84;12.91)
1 | | Proteinuria mg/dL(<100) | 17.55 (13.60;22.64)
1 | | ALT Grade 3 (>5–10 times the ULN) | 36.97 (32.18;42.46)
Adefovir dipivoxil + Lamivudine ^43^ | 1 | End | HBV DNA loss | 35.16 (30.61;40.39)
Adefovir dipivoxil + Lamivudine ^43^
Adefovir dipivoxil + Lamivudine ^43^ | 1 | End | HBeAg loss | 15.03 (13.64;16.56)
Adefovir dipivoxil + Lamivudine ^43^
Adefovir dipivoxil + Lamivudine ^43^ | 1 | End | HBeAg seroconversion | 5.00 (4.73;5.29)
Adefovir dipivoxil + Lamivudine ^43^
Adefovir dipivoxil + Lamivudine ^43^ | 1 | End | Normalization ALT | 49.90 (43.44;57.32)
Adefovir dipivoxil + Lamivudine ^43^
Adefovir dipivoxil + Lamivudine ^43^ | 1 | End | HBsAg loss | 5.00 (4.73;5.29)
Adefovir dipivoxil + Lamivudine ^43^
Adefovir dipivoxil + Lamivudine ^43^ | 1 | | Any adverse event | 90.02 (82.84;97.82)
Adefovir dipivoxil + Lamivudine ^43^
Adefovir dipivoxil + Lamivudine ^43^ | 1 | | Asthenia | 49.90 (43.44;57.32)
Adefovir dipivoxil + Lamivudine ^43^
Adefovir dipivoxil + Lamivudine ^43^ | 1 | | Headache | 29.96 (26.45;33.95)
Adefovir dipivoxil + Lamivudine ^43^
Adefovir dipivoxil + Lamivudine ^43^ | 1 | | Pharyngitis | 5.00 (4.73;5.29)
Adefovir dipivoxil + Lamivudine ^43^
Adefovir dipivoxil + Lamivudine ^43^ | 1 | | Abdominal pain | 29.96 (26.45;33.95)
Adefovir dipivoxil + Lamivudine ^43^
Adefovir dipivoxil + Lamivudine ^43^ | 1 | | Back pain | 15.03 (13.64;16.56)
Adefovir dipivoxil + Lamivudine ^43^
Adefovir dipivoxil + Lamivudine ^43^ | 1 | | Nausea | 20.09 (17.98;22.44)
Adefovir dipivoxil + Lamivudine ^43^
Adefovir dipivoxil + Lamivudine ^43^ | 1 | | Pain | 20.09 (17.98;22.44)
Adefovir dipivoxil + Lamivudine ^43^
Adefovir dipivoxil + Lamivudine ^43^ | 1 | | Infection | 15.03 (13.64;16.56)
Adefovir dipivoxil + Lamivudine ^43^
Adefovir dipivoxil + Lamivudine ^43^ | 1 | | ALT Grade 3 (>5–10 times ULN) | 2.51 (2.41;2.62)
Adefovir dipivoxil + Lamivudine ^43^
Adefovir dipivoxil + Lamivudine ^43^ | 1 | | Insomnia | 2.51 (2.41;2.62)
Adefovir dipivoxil + Lamivudine ^43^
1 | | Rash | 2.51 (2.41;2.62)
1 | | Fever | 2.51 (2.41;2.62)
1 | | Increased cough | 2.51 (2.41;2.62)
1 | | Gastroenteritis | 2.51 (2.41;2.62)
1 | | Grade4 (>10 times the ULN) | 2.51 (2.41;2.62)
1 | | Grade4 (>5 times the ULN) | 2.51 (2.41;2.62)
1 | | Grade4 (>30 mg/dL; <500 mg/dL) | 2.51 (2.41;2.62)
1 | | Grade4 (4+) | 2.51 (2.41;2.62)
1 | | Sinusitis | 5.00 (4.73;5.29)
1 | | Arthralgia | 5.00 (4.73;5.29)
1 | | ALT Grade 4 >10 times ULN | 5.00 (4.73;5.29)
1 | | Serum glucose Grade3 abnormalities | 5.00 (4.63;5.41)
1 | | Urine Glucose Grade3 | 5.00 (4.73;5.29)
1 | | Diarrhea | 9.97 (9.18;10.84)
1 | | Rhinitis | 9.97 (9.18;10.84)
1 | | Amylase Grade3 (>2–5 ULN) | 9.97 (9.18;10.84)
1 | | Bacterial infection | 15.03 (13.64;16.56)
Entecavir^73,^,^75,101^ | 1 | End | Improved histology | 43.51 (31.63;59.85)
Entecavir^73,^,^75,101^
Entecavir^73,^,^75,101^ | 2 | End | Resistance | 19.76 (7.85;49.71)
Entecavir^73,^,^75,101^
Entecavir^73,^,^75,101^ | 3 | End | Failure | 5.42 (1.89;15.52)
Entecavir^73,^,^75,101^
Entecavir^73,^,^75,101^ | 3 | End | Combined | 42.68 (26.13;69.70)
Entecavir^73,^,^75,101^
Entecavir^73,^,^75,101^ | 3 | End | Normalization ALT | 73.28 (62.93;85.34)
Entecavir^73,^,^75,101^
Entecavir^73,^,^75,101^ | 2 | End | HBeAg loss | 14.81 (6.83;32.11)
Entecavir^73,^,^75,101^
Entecavir^73,^,^75,101^ | 3 | End | HBeAg seroconversion | 16.98 (8.79;32.81)
Entecavir^73,^,^75,101^
Entecavir^73,^,^75,101^ | 3 | End | Flare | 2.08 (1.02;4.27)
Entecavir^73,^,^75,101^
Entecavir^73,^,^75,101^ | 3 | End | Death | 1.00 (0.98;1.02)
Entecavir^73,^,^75,101^
Entecavir^73,^,^75,101^ | 2 | End | HBV DNA loss | 73.20 (65.17;82.23)
Entecavir^73,^,^75,101^
Entecavir^73,^,^75,101^ | 2 | End | HBsAg loss | 3.74 (1.09;12.87)
Entecavir^73,^,^75,101^
Entecavir^73,^,^75,101^ | 1 | End | HBsAg seroconversion | 1.99 (1.96;2.03)
Entecavir^73,^,^75,101^
Entecavir^73,^,^75,101^ | 1 | End | Relapse | 4.02 (3.94;4.09)
Entecavir^73,^,^75,101^
1 | End | Decompensation | 0.14 (0.14;0.15)
2 | Followup off treatment | Combined | 9.84 (4.06;23.85)
1 | Followup off treatment | Flare | 1.00 (0.98;1.02)
1 | Followup off treatment | Death | 1.00 (0.98;1.02)
1 | Followup off treatment | HBV DNA loss | 7.03 (6.89;7.17)
1 | Followup off treatment | Relapse | 1.99 (1.96;2.03)
1 | Followup off treatment | Decompensation | 0.14 (0.14;0.15)
2 | All | Any adverse event | 85.36 (82.63;88.19)
2 | All | Serious adverse events | 6.84 (3.97;11.80)
1 | All | Discontinuations because of adverse events | 1.00 (0.98;1.02)
1 | All | Discontinuation due to adverse effects | 0.14 (0.14;0.15)
1 | All | ALT >2× baseline and >5× ULN | 1.00 (0.99;1.01)
1 | All | ALT > 2× reference value and >5× ULN | 10.00 (9.97;10.03)
1 | All | Any adverse effect | 77.20 (77.17;77.23)*
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^ | 3 | End | Normalization ALT | 46.38 (27.43;78.42)
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^ | 5 | End | HBV DNA loss | 46.97 (34.69;63.61)
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^ | 4 | End | HBeAg loss | 50.78 (33.81;76.25)
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^ | 3 | End | HBeAg seroconversion | 40.09 (20.44;78.63)
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^ | 2 | End | HBsAg loss | 6.14 (3.47;10.88)
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^ | 1 | End | Combined | 24.99 (17.81;35.07)
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^ | 1 | End | Resistance | 7.03 (6.50;7.60)
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^ | 1 | End | Improved histology | 25.03 (20.57;30.45)
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^ | 2 | End | Death | 6.83 (3.05;15.27)
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^ | 1 | End | Flare | 5.99 (5.43;6.61)
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^ | 6 | Followup off treatment | Normalization ALT | 36.49 (26.10;51.03)
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^ | 11 | Followup off treatment | HBV DNA loss | 26.97 (18.34;39.67)
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^ | 10 | Followup off treatment | HBeAg loss | 42.96 (32.25;57.23)
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^ | 5 | Followup off treatment | HBeAg seroconversion | 31.86 (19.64;51.66)
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^ | 8 | Followup off treatment | HBsAg loss | 7.41 (4.20;13.07)
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^ | 8 | Followup off treatment | Combined | 13.49 (8.41;21.64)
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^ | 3 | Followup off treatment | Resistance | 7.64 (4.46;13.08)
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^ | 3 | Followup off treatment | Relapse | 2.24 (1.72;2.91)
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^ | 2 | Followup off treatment | Death | 4.16 (2.27;7.62)
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^ | 2 | Followup off treatment | HBsAg seroconversion | 6.32 (0.66;60.79)
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^ | 2 | Followup off treatment | Improved histology | 26.91 (15.24;47.50)
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^ | 1 | Followup off treatment | Cirrhosis | 8.92 (2.86;27.81)
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^ | 1 | Followup off treatment | Failure | 25.03 (22.69;27.61)
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^ | 1 | Followup off treatment | Mutation | 0.73 (0.71;0.74)
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^ | 1 | | Abdominal discomfort and pain | 33.00 (32.89;33.11)
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^ | 1 | | Adverse effects | 75.00 (74.92;75.08)
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^ | 1 | | Anorexia | 47.00 (46.89;47.11)
1 | | Arthralgia | 33.00 (32.89;33.11)
1 | | Arthralgia | 8.00 (7.90;8.10)
1 | | Collapse after dizziness | 2.00 (1.97;2.03)
1 | | Depression | 4.00 (3.93;4.07)
1 | | Diarrhea | 23.00 (22.90;23.10)
1 | | Discontinuation due to depression | 3.00 (2.94;3.06)
1 | | Dizziness | 27.00 (26.90;27.10)
1 | | Dose reduction due to depression, fatigue, hair loss, and headache | 11.00 (10.92;11.08)
1 | | Fatigue | 48.00 (47.82;48.18)
1 | | Fever/chills | 61.00 (60.89;61.11)
1 | | Hair loss and alopecia | 30.00 (29.90;30.10)
1 | | Headache | 67.00 (66.89;67.11)
1 | | Infections | 8.00 (7.90;8.10)
1 | | Jaundice | 4.00 (3.93;4.07)
1 | | Malaise and fatigue | 100.00 (100.00;100.00)
1 | | Marrow suppression | 8.00 (7.90;8.10)
1 | | mouth dryness | 19.00 (18.83;19.17)
1 | | Muscle pain | 57.00 (56.89;57.11)
1 | | Nausea | 12.00 (11.88;12.12)
1 | | Nausea and vomiting | 49.00 (48.89;49.11)
1 | | Discontinuation due to drug-related adverse effects | 3.00 (2.97;3.03)
1 | | Discontinuation due to psychosis | 3.00 (2.94;3.06)
1 | | Reduction in dose because of severe side effects | 8.00 (7.90;8.10)
1 | | Viral respiratory infections | 53.00 (52.89;53.11)
5 | | Discontinuation due to adverse effects | 2.91 (1.41;5.99)
1 | | Discontinuation due to neuropsychiatric disorder | 3.63 (1.93;6.80)
2 | | Reduction in dose due to adverse effects | 20.70 (18.64;22.98)*
Interferon Alfa-2b + Corticosteroid^90^–^96,103^ | 2 | End | Combined | 39.50 (33.32;46.83)
Interferon Alfa-2b + Corticosteroid^90^–^96,103^
Interferon Alfa-2b + Corticosteroid^90^–^96,103^ | 1 | End | Death | 2.77 (2.56;3.00)
Interferon Alfa-2b + Corticosteroid^90^–^96,103^
Interferon Alfa-2b + Corticosteroid^90^–^96,103^ | 3 | End | HBsAg loss | 9.22 (6.42;13.24)
Interferon Alfa-2b + Corticosteroid^90^–^96,103^
Interferon Alfa-2b + Corticosteroid^90^–^96,103^ | 2 | End | HBV DNA loss | 37.38 (23.78;58.77)
Interferon Alfa-2b + Corticosteroid^90^–^96,103^
Interferon Alfa-2b + Corticosteroid^90^–^96,103^ | 1 | End | Resistance | 47.85 (42.56;53.80)*
Interferon Alfa-2b + Corticosteroid^90^–^96,103^
Interferon Alfa-2b + Corticosteroid^90^–^96,103^ | 2 | End | HBeAg loss | 42.02 (19.39;91.04)
Interferon Alfa-2b + Corticosteroid^90^–^96,103^
Interferon Alfa-2b + Corticosteroid^90^–^96,103^ | 2 | Followup off treatment | Combined | 7.03 (2.37;20.89)
Interferon Alfa-2b + Corticosteroid^90^–^96,103^
Interferon Alfa-2b + Corticosteroid^90^–^96,103^ | 1 | Followup off treatment | Death | 5.00 (4.45;5.63)
Interferon Alfa-2b + Corticosteroid^90^–^96,103^
Interferon Alfa-2b + Corticosteroid^90^–^96,103^ | 2 | Followup off treatment | Relapse | 3.33 (2.11;5.26)
Interferon Alfa-2b + Corticosteroid^90^–^96,103^
Interferon Alfa-2b + Corticosteroid^90^–^96,103^ | 3 | Followup off treatment | HBsAg loss | 17.25 (5.51;54.07)
6 | Followup off treatment | HBV DNA loss | 24.44 (16.31;36.63)
2 | Followup off treatment | Resistance | 18.36 (9.25;36.45)
1 | Followup off treatment | Cirrhosis | 9.97 (9.04;11.00)
3 | Followup off treatment | Normalization ALT | 35.77 (20.48;62.47)
3 | Followup off treatment | HBeAg loss | 45.64 (33.35;62.46)
2 | Followup off treatment | HBeAg seroconversion | 51.10 (44.58;58.58)
1 | | Reduction in dose because of severe side effects | 8.00 (7.90;8.10)
1 | | Leucopenia | 20.00 (19.79;20.21)
1 | | Discontinuation due to adverse effects | 2.94 (2.87;3.01)
1 | | Reduction in dose due to adverse effects | 12.00 (11.86;12.14)
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^ | 3 | End | Mutation | 3.30 (1.55;7.06)
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^ | 1 | End | HBsAg loss | 5.99 (5.75;6.24)
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^ | 4 | End | HBeAg seroconversion | 31.30 (13.42;73.00)
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^ | 3 | End | Failure | 13.17 (8.74;19.85)
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^ | 4 | End | HBeAg loss | 38.85 (21.64;69.72)
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^ | 4 | End | Normalization ALT | 44.07 (22.58;86.02)
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^ | 6 | End | HBV DNA loss | 59.03 (41.91;83.15)
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^ | 5 | End | Improved histology | 36.77 (31.13;43.43)
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^ | 1 | End | Flare | 1.52 (1.46;1.58)
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^ | 1 | End | Relapse | 4.02 (3.86;4.18)
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^ | 2 | End | Combined | 55.02 (31.63;95.72)
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^ | 1 | End | Resistance | 57.02 (50.92;63.85)
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^ | 1 | Followup off treatment | Mutation | 0.66 (0.66;0.67)
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^ | 2 | Followup off treatment | HBsAg loss | 2.54 (0.52;12.36)
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^ | 6 | Followup off treatment | HBeAg seroconversion | 35.15 (20.28;60.93)
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^ | 2 | Followup off treatment | Failure | 21.96 (19.92;24.22)
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^ | 5 | Followup off treatment | HBeAg loss | 39.96 (29.41;54.30)
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^ | 6 | Followup off treatment | Normalization ALT | 61.61 (50.09;75.77)
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^ | 7 | Followup off treatment | HBV DNA loss | 49.14 (28.67;84.21)
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^ | 1 | Followup off treatment | Improved histology | 27.94 (26.07;29.94)
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^ | 1 | Followup off treatment | Flare | 5.00 (4.72;5.31)
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^ | 2 | Followup off treatment | Relapse | 6.68 (3.57;12.50)
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^ | 2 | Followup off treatment | Combined | 32.39 (27.06;38.76)
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^ | 1 | | ALT> 2 than at baseline | 1.26 (0.81;1.96)
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^ | 4 | | Discontinuation due AE | 4.77 (3.34;6.81)
1 | | Arthralgia | 11.94 (11.30;12.62)
1 | | Dizziness | 11.94 (11.30;12.62)
1 | | Abnormal enzymes | 12.94 (12.24;13.67)
1 | | Abdominal discomfort | 14.01 (13.26;14.81)
1 | | Abnormal ALT/AST | 15.96 (15.10;16.87)
1 | | Pain | 15.96 (15.10;16.87)
1 | | Musculoskeletal pain | 15.96 (15.10;16.87)
4 | | Diarrhea | 14.08 (7.59;26.10)
1 | | Decreased WBCs | 25.03 (23.35;26.82)
1 | | Rheumatism | 25.03 (23.35;26.82)
2 | | Depression | 11.35 (1.52;84.71)
1 | | Feeding problems | 29.96 (27.57;32.56)
2 | | Viral respiratory in | 38.48 (34.75;42.60)
1 | | Anorexia | 38.86 (36.26;41.65)
1 | | Hair loss and alopecia | 38.86 (36.26;41.65)
1 | | Nausea and vomiting | 42.95 (39.52;46.67)
2 | | Muscle pain | 46.53 (43.87;49.34)
1 | | Nausea/vomiting | 59.15 (54.43;64.27)
1 | | Fever/chills | 60.95 (56.87;65.32)
4 | | Headache | 44.65 (43.37;45.97)
1 | | Malaise and fatigue | 87.36 (82.65;92.34)
1 | | Malaise/fatigue | 94.63 (90.78;98.65)
2 | | Fever | 94.63 (90.78;98.65)
3 | | Albumin: 2.0–2.4 g/d | 3.00 (2.89;3.12)
2 | | Influenza-like symptoms | 64.18 (58.99;69.82)
Interferon Alfa-2b + Placebo ^67,93^ | 1 | End | HBeAg loss | 83.10 (76.83;89.87)
Interferon Alfa-2b + Placebo ^67,93^
Interferon Alfa-2b + Placebo ^67,93^ | 1 | End | HBV DNA loss | 83.10 (76.83;89.87)
Interferon Alfa-2b + Placebo ^67,93^
Interferon Alfa-2b + Placebo ^67,93^ | 1 | End | Normalization ALT | 83.93 (77.60;90.78)
Interferon Alfa-2b + Placebo ^67,93^
Interferon Alfa-2b + Placebo ^67,93^ | 1 | End | HBeAg seroconversion | 92.76 (87.46;98.38)
Interferon Alfa-2b + Placebo ^67,93^
Interferon Alfa-2b + Placebo ^67,93^ | 1 | Followup off treatment | Mutation | 0.73 (0.71;0.74)
Interferon Alfa-2b + Placebo ^67,93^
Interferon Alfa-2b + Placebo ^67,93^ | 1 | Followup off treatment | Failure | 25.03 (22.69;27.61)
Interferon Alfa-2b + Placebo ^67,93^
Interferon Alfa-2b + Placebo ^67,93^ | 1 | Followup off treatment | Improved histology | 35.87 (31.89;40.35)
Interferon Alfa-2b + Placebo ^67,93^
Interferon Alfa-2b + Placebo ^67,93^ | 1 | Followup off treatment | HBeAg loss | 75.19 (65.55;86.25)
Interferon Alfa-2b + Placebo ^67,93^
Interferon Alfa-2b + Placebo ^67,93^ | 1 | Followup off treatment | HBV DNA loss | 75.19 (66.85;84.57)
Interferon Alfa-2b + Placebo ^67,93^
Interferon Alfa-2b + Placebo ^67,93^ | 1 | Followup off treatment | Normalization ALT | 75.94 (68.86;83.76)
Interferon Alfa-2b + Placebo ^67,93^
Interferon Alfa-2b + Placebo ^67,93^ | 1 | Followup off treatment | HBeAg seroconversion | 92.76 (88.98;96.70)
Interferon Alfa-2b + Placebo ^67,93^
Interferon Alfa-2b + Placebo ^67,93^ | 1 | Followup off treatment | Combined | 8.67 (2.95;25.46)
Interferon Alfa-2b + Placebo ^67,93^
Interferon Alfa-2b + Placebo ^67,93^ | 1 | | Discontinuation due to adverse effects | 0.71 (0.70;0.73)
Interferon Alfa-2b + Placebo ^67,93^
1 | | Hepatitis flares (ALT levels >500 IU/l and >2′ baseline) | 9.00 (8.93;9.07)
1 | | Hepatitis flares (ALT levels >500 IU/l and >2′ baseline) | 11.00 (10.93;11.07)
1 | | Diarrhea | 23.00 (22.90;23.10)
1 | | Dizziness | 27.00 (26.90;27.10)
1 | | Hair loss and alopecia | 30.00 (29.90;30.10)
1 | | Abdominal discomfort and pain | 33.00 (32.89;33.11)
1 | | Arthralgia | 33.00 (32.89;33.11)
1 | | Anorexia | 47.00 (46.89;47.11)
1 | | Nausea and vomiting | 49.00 (48.89;49.11)
1 | | Viral respiratory infections | 53.00 (52.89;53.11)
1 | | Muscle pain | 57.00 (56.89;57.11)
1 | | Fever/chills | 61.00 (60.89;61.11)
1 | | Headache | 67.00 (66.89;67.11)
1 | | Malaise and fatigue | 100.00 (100.00;100.00)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 12 | End | HBeAg loss | 19.08 (11.82;30.78)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 15 | End | HBeAg seroconversion | 15.42 (9.99;23.80)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 11 | End | Improved histology | 30.76 (22.17;42.67)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 11 | End | Failure | 10.04 (7.65;13.18)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 17 | End | HBV DNA loss | 43.86 (32.37;59.44)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 15 | End | Normalization ALT | 38.41 (25.65;57.51)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 4 | End | Resistance | 38.06 (27.41;52.85)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 4 | End | HBsAg loss | 1.99 (1.29;3.07)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 5 | End | Flare | 7.74 (5.84;10.27)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 3 | End | Death | 1.00 (0.99;1.01)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 8 | End | Combined | 27.95 (19.58;39.89)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 5 | End | Relapse | 12.62 (5.93;26.86)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | End | Decompensation | 0.14 (0.14;0.14)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | End | HBsAg seroconversion | 5.00 (4.81;5.20)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 6 | End | Mutation | 13.45 (6.59;27.45)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 7 | Followup off treatment | HBeAg loss | 32.22 (26.08;39.81)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 7 | Followup off treatment | HBeAg seroconversion | 24.49 (14.88;40.31)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 2 | Followup off treatment | Improved histology | 34.12 (32.73;35.57)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 2 | Followup off treatment | Failure | 11.94 (11.04;12.92)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 5 | Followup off treatment | HBV DNA loss | 9.30 (4.83;17.91)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 5 | Followup off treatment | Normalization ALT | 39.26 (23.18;66.48)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 3 | Followup off treatment | HBsAg loss | 1.56 (0.80;3.05)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 3 | Followup off treatment | Flare | 4.82 (1.96;11.90)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 3 | Followup off treatment | Death | 1.00 (0.99;1.01)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 6 | Followup off treatment | Combined | 9.89 (4.83;20.26)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 4 | Followup off treatment | Relapse | 14.06 (4.72;41.86)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 2 | Followup off treatment | Decompensation | 2.00 (1.15;3.48)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | Followup off treatment | Mutation | 23.00 (21.51;24.59)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 3 | | >1 Reported adverse | 47.41 (31.02;72.47)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | >1 Reported serious AE | 1.99 (1.97;2.02)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 4 | | Abdominal discomfort | 8.02 (4.81;13.38)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | Abdominal discomfort or pain | 15.26 (12.66;18.39)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | Abdominal distention | 8.00 (7.82;8.20)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | Abdominal pain | 26.05 (23.00;29.51)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | Abnormal ALT/AST | 17.99 (17.26;18.76)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | Abnormal enzymes (amylase/CPK) | 15.96 (15.31;16.64)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 2 | | Abnormal liver function tests | 7.04 (4.30;11.53)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | Acne and folliculitis | 3.66 (2.79;4.81)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | Albumin: 2.0–2.4 g/d | 3.00 (2.89;3.12)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | Allergic rashes | 1.99 (1.92;2.07)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 2 | | Alopecia | 2.51 (1.98;3.19)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | ALT > 2× reference value and >5× ULN | 5.00 (4.91;5.10)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | ALT >2× baseline and >5× ULN | 16.95 (16.29;17.62)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | ALT »2 times above base-line levels | 26.05 (24.09;28.17)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 2 | | ALT> 2 than at baseline and >500U/l | 3.02 (1.57;5.80)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | ALT »3 times above base-line levels | 15.17 (6.66;34.54)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | ALT Grade 3 (>5–10 times the ULN) | 2.64 (2.53;2.75)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | ALT Grade 4 >10 times the ULN) | 15.96 (14.28;17.83)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | Amylase >2× upper limit of normal | 3.66 (2.79;4.81)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | Amylase Grade3 (>2–5 times the ULN) | 15.96 (14.28;17.83)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | Amylase: value 3.1–10 times the baseline value and >10 times the baseline value | 1.00 (0.98;1.02)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | Anorexia | 5.00 (4.87;5.14)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | Any adverse effect | 66.11 (41.30;105.81)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 3 | | Any adverse event | 36.11 (24.98;52.19)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 4 | | Arthralgia | 5.74 (4.53;7.27)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | AST Grade3 (>5–10 times the ULN) | 5.00 (4.67;5.36)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | Asthenia | 32.14 (27.98;36.91)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | At least one adverse event | 5.00 (4.93;5.07)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | At least one adverse effect | 68.03 (61.68;75.04)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 2 | | Back pain | 4.77 (3.18;7.15)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | Bacterial infection | 2.64 (2.53;2.75)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | Chest symptoms | 2.45 (1.94;3.09)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 2 | | Constipation | 3.83 (2.91;5.05)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 5 | | Cough | 14.63 (10.43;20.53)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | CPK >5× upper limit | 4.74 (3.21;7.01)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | Creatine kinase: value 7–9.9 times the baseline value and at least 10 times the baseline value | 7.03 (6.63;7.45)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | Decreased appetite | 1.99 (1.97;2.02)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | Decreased neutrophil count | 1.00 (0.98;1.02)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | Decreased phosphate level | 1.99 (1.92;2.07)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | Decreased WBCs | 1.00 (0.99;1.01)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 4 | | Depression | 4.02 (2.47;6.53)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 12 | | Diarrhea | 9.44 (7.31;12.18)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 7 | | Discontinuation due to adverse effect | 3.76 (2.61;5.43)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 8 | | Dizziness | 5.16 (4.55;5.87)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 3 | | Dyspepsia | 6.26 (4.98;7.86)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | Ear, nose, and throat infection | 21.33 (19.20;23.69)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | Dose modification due to adverse effects | 0.18 (0.18;0.19)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | Dose modification due to Laboratory abnormality: Alanine aminotransferase elevation, Neutropenia, and thrombocytopenia | 0.18 (0.18;0.19)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | Eczema | 3.66 (2.79;4.81)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | events of the hepatobiliary tract and pancreas | 4.60 (2.00;10.57)
4 | | Fatigue | 9.03 (6.36;12.82)
1 | | Feeding problems | 1.99 (1.97;2.02)
4 | | Fever | 5.89 (5.16;6.71)
1 | | Fever/chills | 7.03 (6.74;7.33)
1 | | Gastroenteritis | 15.96 (14.28;17.83)
1 | | Gastrointestinal events | 9.58 (7.78;11.81)
1 | | Grade III abnormality in ALT | 14.14 (7.12;28.07)
1 | | Grade III or IV laboratory abnormalities in Alanine aminotransferase | 9.97 (9.41;10.58)
1 | | Grade III or IV laboratory abnormalities in Albumin | 0.70 (0.69;0.72)
1 | | Grade III or IV laboratory abnormalities in Amylase | 0.70 (0.69;0.72)
1 | | Grade III or IV laboratory abnormalities in Creatine kinase | 9.00 (8.94;9.06)
1 | | Grade III or IV laboratory abnormalities in Lipase | 9.00 (8.94;9.06)
1 | | Grade III or IV laboratory abnormalities in Platelets | 0.70 (0.69;0.72)
1 | | Grade IV abnormality in ALT | 1.46 (0.35;6.03)
1 | | Grade4 (>10 times the ULN) | 11.02 (10.00;12.15)
1 | | Grade4 (>30 mg/dL; <500 mg/dL) | 2.64 (2.53;2.75)
1 | | Grade4 (4+) | 2.64 (2.53;2.75)
1 | | Grade4 (>5 times the ULN) | 2.64 (2.53;2.75)
1 | | Hair loss | 1.99 (1.97;2.02)
1 | | Hair loss and alopecia | 9.97 (9.57;10.40)
1 | | Hair loss or alopecia | 1.99 (1.97;2.02)
13 | | Headache | 11.93 (9.48;15.01)
1 | | Hypoglycemia | 3.65 (3.06;4.36)
1 | | Increased alkaline phosphatase level | 2.00 (1.96;2.04)
1 | | Increased ALT level | 24.00 (23.89;24.11)
1 | | Increased cough | 15.96 (14.28;17.83)
2 | | Increased Creatine phosphokinase level | 4.16 (2.49;6.94)
1 | | Infection | 5.00 (4.67;5.36)
1 | | Influenza | 20.91 (19.33;22.61)
3 | | Influenza-like symptoms | 17.27 (14.63;20.40)
2 | | Insomnia | 6.46 (5.30;7.87)
1 | | Leucopenia | 5.00 (4.98;5.02)
1 | | Lipase: value 2.6 to five times ULNand >5 times the upper limit of normal | 3.00 (2.96;3.04)
1 | | Liver symptoms | 5.00 (4.98;5.02)
1 | | Local erythematous reaction | 1.00 (0.97;1.03)
1 | | Malaise | 14.00 (13.91;14.09)
3 | | Malaise and fatigue | 17.98 (14.62;22.12)
4 | | Malaise or fatigue | 18.47 (12.74;26.78)
6 | | Muscle pain | 4.79 (2.87;8.00)
3 | | Musculoskeletal pain | 4.77 (2.43;9.36)
2 | | Nasal signs and symptoms | 8.93 (7.83;10.18)
1 | | Nasopharyngitis | 5.00 (4.76;5.25)
3 | | Nausea | 3.96 (3.07;5.12)
4 | | Nausea and vomiting | 8.13 (6.08;10.86)
5 | | Nausea or vomiting | 8.77 (5.52;13.94)
1 | | Neurological events | 6.94 (6.04;7.98)
2 | | Pain | 4.49 (2.69;7.51)
1 | | Paresthesias | 3.00 (2.89;3.12)
1 | | Pharyngitis | 32.14 (27.98;36.91)
1 | | Pharyngolaryngeal pain | 15.96 (14.76;17.26)
1 | | Pigmentary skin disorders | 3.66 (2.79;4.81)
1 | | Platelets: value of 20 000–49 000/mm3 and less than 20 000/mm3 | 3.00 (2.96;3.04)
1 | | Pruritis | 5.00 (4.91;5.10)
1 | | Pyrexia | 4.02 (3.96;4.07)
4 | | Rash | 7.45 (6.16;9.01)
1 | | Reduced appetite | 1.00 (0.98;1.02)
1 | | Respiratory infection | 35.16 (33.81;36.57)
1 | | Rheumatism | 5.00 (4.87;5.14)
1 | | Rhinitis | 26.05 (23.00;29.51)
1 | | Severe Myalgia | 1.19 (1.14;1.23)
1 | | Serum glucose Grade3 (30–39 mg/dL; 251–500 mg/dL) | 15.96 (14.28;17.83)
1 | | Sinusitis | 26.05 (23.00;29.51)
2 | | Skin rash | 4.84 (3.37;6.97)
1 | | Sleep disorder | 7.03 (6.63;7.45)
1 | | Sleep disturbance | 5.00 (4.91;5.10)
1 | | Sore throat | 7.03 (6.84;7.23)
1 | | Temperature regulation disturbance | 8.94 (8.11;9.84)
1 | | Throat and tonsil discomfort/pain | 22.53 (21.82;23.27)
1 | | Throat discomfort or pain | 14.37 (12.76;16.18)
2 | | Upper abdominal pain | 5.63 (4.89;6.49)
1 | | Upper respiratory tract infection | 6.53 (4.72;9.03)
1 | | Upper respiratory tract symptoms | 38.00 (37.87;38.13)
1 | | Upper respiratory viral infection | 5.00 (4.98;5.02)
1 | | Urine Glucose Grade3 (3+) | 21.00 (20.83;21.17)
1 | | Vertigo | 3.66 (2.79;4.81)
1 | | Viral respiratory infection | 27.70 (25.30;30.32)
1 | | Viral respiratory infections (multiple) | 9.48 (3.53;25.46)
1 | | Vomiting or diarrhea | 6.00 (5.94;6.06)
1 | | Weight loss (>10%) | 2.00 (1.96;2.04)
1 | | Withdrawal due to side effects | 1.35 (1.32;1.39)
Peginterferon alfa-2a ^56,116^ | 1 | End | HBeAg loss | 29.96 (28.74;31.24)
Peginterferon alfa-2a ^56,116^
Peginterferon alfa-2a ^56,116^ | 1 | End | HBeAg seroconversion | 27.11 (26.01;28.26)
Peginterferon alfa-2a ^56,116^
Peginterferon alfa-2a ^56,116^ | 1 | End | Normalization ALT | 38.86 (37.28;40.51)
Peginterferon alfa-2a ^56,116^
Peginterferon alfa-2a ^56,116^ | 1 | End | Combined | 9.97 (9.70;10.26)
Peginterferon alfa-2a ^56,116^
Peginterferon alfa-2a ^56,116^ | 1 | End | HBV DNA loss | 25.03 (24.01;26.09)
Peginterferon alfa-2a ^56,116^
Peginterferon alfa-2a ^56,116^ | 1 | End | Flare | 5.00 (4.93;5.07)
Peginterferon alfa-2a ^56,116^
Peginterferon alfa-2a ^56,116^ | 1 | End | Mutation | 0.18 (0.18;0.19)
Peginterferon alfa-2a ^56,116^
Peginterferon alfa-2a ^56,116^ | 2 | Follow | HBeAg loss | 33.60 (31.77;35.53)
Peginterferon alfa-2a ^56,116^
Peginterferon alfa-2a ^56,116^ | 2 | Follow | HBeAg seroconversion | 31.98 (29.91;34.20)
Peginterferon alfa-2a ^56,116^
Peginterferon alfa-2a ^56,116^ | 2 | Follow | Normalization ALT | 37.26 (34.12;40.70)
Peginterferon alfa-2a ^56,116^
Peginterferon alfa-2a ^56,116^ | 2 | Follow | Combined | 23.88 (21.65;26.34)
Peginterferon alfa-2a ^56,116^
Peginterferon alfa-2a ^56,116^ | 1 | Follow | HBV DNA loss | 14.01 (13.63;14.41)
Peginterferon alfa-2a ^56,116^
Peginterferon alfa-2a ^56,116^ | 1 | Follow | Improved histology | 38.09 (36.54;39.71)
Peginterferon alfa-2a ^56,116^
Peginterferon alfa-2a ^56,116^ | 1 | Follow | Death | 0.18 (0.18;0.19)
Peginterferon alfa-2a ^56,116^
Peginterferon alfa-2a ^56,116^ | 1 | | Discontinuation due to AE | 3.00 (2.96;3.05)
Peginterferon alfa-2a ^56,116^
Peginterferon alfa-2a ^56,116^ | 1 | | >1 Reported serious AE | 4.02 (3.96;4.07)
Peginterferon alfa-2a ^56,116^
Peginterferon alfa-2a ^56,116^ | 2 | | Cough | 8.04 (6.56;9.84)
Peginterferon alfa-2a ^56,116^
Peginterferon alfa-2a ^56,116^ | 1 | | Dyspepsia | 5.00 (4.93;5.07)
Peginterferon alfa-2a ^56,116^
Peginterferon alfa-2a ^56,116^ | 1 | | Depression | 5.00 (4.93;5.07)
Peginterferon alfa-2a ^56,116^
Peginterferon alfa-2a ^56,116^ | 1 | | Sore throat | 5.99 (5.91;6.07)
Peginterferon alfa-2a ^56,116^
Peginterferon alfa-2a ^56,116^ | 1 | | Gingival bleeding | 5.99 (5.91;6.07)
1 | | Dose modification due to adverse effects | 7.03 (6.84;7.23)
| | Dose modification due to laboratory abnormality: alanine aminotransferase elevation, neutropenia, and thrombocytopenia | 36.97 (35.46;38.54)
2 | | Insomnia | 12.39 (9.30;16.52)
1 | | Rigors | 7.03 (6.84;7.23)
1 | | Upper abdominal pain | 7.03 (6.84;7.23)
1 | | Upper respiratory tract infection | 13.35 (9.25;19.26)
1 | | Anorexia | 13.96 (9.68;20.11)
2 | | Diarrhea | 12.15 (9.75;15.15)
2 | | Dizziness | 14.19 (11.26;17.89)
2 | | Nausea | 12.45 (10.30;15.05)
1 | | Injection-site reaction | 9.03 (8.78;9.28)
1 | | Arthralgia | 9.03 (8.78;9.28)
1 | | Rash | 9.97 (9.70;10.26)
1 | | Pruritus | 9.97 (9.70;10.26)
1 | | Decreased appetite | 15.03 (14.62;15.45)
2 | | Alopecia | 26.31 (21.71;31.89)
2 | | Fatigue | 28.96 (24.23;34.61)
2 | | Myalgia | 35.59 (30.05;42.15)
2 | | Headache | 38.55 (32.46;45.78)
2 | | Pyrexia | 56.61 (50.87;63.00)
1 | | >1 reported AE | 89.12 (86.69;91.63)
Peginterferon alfa-2a+Lamivudine ^56^ | 1 | End | HBeAg seroconversion | 24.05 (23.07;25.07)
Peginterferon alfa-2a+Lamivudine ^56^
Peginterferon alfa-2a+Lamivudine ^56^ | 1 | End | HBeAg loss | 27.11 (26.01;28.26)
Peginterferon alfa-2a+Lamivudine ^56^
Peginterferon alfa-2a+Lamivudine ^56^ | 1 | End | HBV DNA loss | 68.72 (65.92;71.64)
Peginterferon alfa-2a+Lamivudine ^56^
Peginterferon alfa-2a+Lamivudine ^56^ | 1 | End | Normalization ALT | 46.06 (44.19;48.02)
Peginterferon alfa-2a+Lamivudine ^56^
Peginterferon alfa-2a+Lamivudine ^56^ | 1 | End | Combined | 15.03 (14.62;15.45)
Peginterferon alfa-2a+Lamivudine ^56^
Peginterferon alfa-2a+Lamivudine ^56^ | 1 | End | Flare | 5.99 (5.91;6.07)
Peginterferon alfa-2a+Lamivudine ^56^
Peginterferon alfa-2a+Lamivudine ^56^ | 1 | End | Mutation | 3.00 (2.96;3.05)
Peginterferon alfa-2a+Lamivudine ^56^
Peginterferon alfa-2a+Lamivudine ^56^ | 1 | Follow | Death | 1.00 (0.99;1.01)
Peginterferon alfa-2a+Lamivudine ^56^
Peginterferon alfa-2a+Lamivudine ^56^ | 1 | Follow | HBV DNA loss | 14.01 (13.63;14.41)
Peginterferon alfa-2a+Lamivudine ^56^
Peginterferon alfa-2a+Lamivudine ^56^ | 1 | Follow | Combined | 20.91 (20.33;21.49)
Peginterferon alfa-2a+Lamivudine ^56^
Peginterferon alfa-2a+Lamivudine ^56^ | 1 | Follow | HBeAg seroconversion | 27.11 (26.01;28.26)
Peginterferon alfa-2a+Lamivudine ^56^
Peginterferon alfa-2a+Lamivudine ^56^ | 1 | Follow | HBeAg loss | 27.94 (26.80;29.12)
Peginterferon alfa-2a+Lamivudine ^56^
Peginterferon alfa-2a+Lamivudine ^56^ | 1 | Follow | Normalization ALT | 38.86 (37.28;40.51)
Peginterferon alfa-2a+Lamivudine ^56^
Peginterferon alfa-2a+Lamivudine ^56^ | 1 | Follow | Improved histology | 40.85 (39.19;42.59)
Peginterferon alfa-2a+Lamivudine ^56^
Peginterferon alfa-2a+Lamivudine ^56^ | 1 | | ≥1 Reported adverse event | 89.00 (88.96;89.04)
Peginterferon alfa-2a+Lamivudine ^56^
Peginterferon alfa-2a+Lamivudine ^56^ | 1 | | ≥1 Reported serious adverse event | 6.00 (5.97;6.03)
Peginterferon alfa-2a+Lamivudine ^56^
Peginterferon alfa-2a+Lamivudine ^56^ | 1 | | Alopecia | 29.00 (28.95;29.05)
Peginterferon alfa-2a+Lamivudine ^56^
Peginterferon alfa-2a+Lamivudine ^56^ | 1 | | Arthralgia | 9.00 (8.97;9.03)
Peginterferon alfa-2a+Lamivudine ^56^
Peginterferon alfa-2a+Lamivudine ^56^ | 1 | | Cough | 7.00 (6.97;7.03)
Peginterferon alfa-2a+Lamivudine ^56^
Peginterferon alfa-2a+Lamivudine ^56^ | 1 | | Decreased appetite | 13.00 (12.96;13.04)
Peginterferon alfa-2a+Lamivudine ^56^
1 | | Depression | 6.00 (5.97;6.03)
1 | | Diarrhea | 10.00 (9.96;10.04)
1 | | Discontinuation due to adverse effects | 4.00 (3.98;4.02)
1 | | Dizziness | 12.00 (11.96;12.04)
1 | | Dose modification due to adverse effects | 8.00 (7.97;8.03)
1 | | Dose modification due to Laboratory abnormality: Alanine aminotransferase elevation, Neutropenia, and thrombocytopenia | 38.00 (37.94;38.06)
1 | | Dyspepsia | 2.00 (1.98;2.02)
1 | | Fatigue | 37.00 (36.94;37.06)
1 | | Gingival bleeding | 6.00 (5.97;6.03)
1 | | Headache | 30.00 (29.95;30.05)
1 | | Injection-site reaction | 6.00 (5.97;6.03)
1 | | Insomnia | 8.00 (7.97;8.03)
1 | | Myalgia | 28.00 (27.95;28.05)
1 | | Nausea | 10.00 (9.96;10.04)
1 | | Pruritus | 10.00 (9.96;10.04)
1 | | Pyrexia | 55.00 (54.94;55.06)
1 | | Rash | 8.00 (7.97;8.03)
1 | | Rigors | 10.00 (9.96;10.04)
1 | | Sore throat | 8.00 (7.97;8.03)
1 | | Upper abdominal pain | 5.00 (4.97;5.03)
1 | | Upper respiratory tract infection | 6.00 (5.97;6.03)
Peginterferon alfa-2b ^81^ | 1 | End | Mutation | 0.32 (0.31;0.33)
Peginterferon alfa-2b ^81^
Peginterferon alfa-2b ^81^ | 1 | End | HBeAg seroconversion | 8.71 (1.91;39.80)
Peginterferon alfa-2b ^81^
Peginterferon alfa-2b ^81^ | 1 | End | Failure | 7.50 (2.20;25.53)
Peginterferon alfa-2b ^81^
Peginterferon alfa-2b ^81^ | 1 | End | HBsAg loss | 5.00 (4.81;5.20)
Peginterferon alfa-2b ^81^
Peginterferon alfa-2b ^81^ | 1 | End | Improved histology | 20.09 (18.94;21.30)
Peginterferon alfa-2b ^81^
Peginterferon alfa-2b ^81^ | 1 | End | Resistance | 14.51 (13.55;15.54)
Peginterferon alfa-2b ^81^
Peginterferon alfa-2b ^81^ | 1 | End | Flare | 24.05 (22.67;25.50)
Peginterferon alfa-2b ^81^
Peginterferon alfa-2b ^81^ | 1 | End | HBeAg loss | 26.05 (24.56;27.63)
Peginterferon alfa-2b ^81^
Peginterferon alfa-2b ^81^ | 1 | End | Normalization ALT | 29.96 (27.71;32.41)
Peginterferon alfa-2b ^81^
Peginterferon alfa-2b ^81^ | 1 | Follow | HBsAg seroconversion | 0.44 (0.43;0.45)
Peginterferon alfa-2b ^81^
Peginterferon alfa-2b ^81^ | 2 | Follow | HBeAg seroconversion | 14.01 (4.38;44.82)
Peginterferon alfa-2b ^81^
Peginterferon alfa-2b ^81^ | 2 | Follow | HBsAg loss | 6.49 (5.55;7.59)
Peginterferon alfa-2b ^81^
Peginterferon alfa-2b ^81^ | 1 | Follow | Improved histology | 8.00 (7.70;8.32)
Peginterferon alfa-2b ^81^
Peginterferon alfa-2b ^81^ | 1 | Follow | Combined | 16.95 (15.98;17.97)
Peginterferon alfa-2b ^81^
Peginterferon alfa-2b ^81^ | 2 | Follow | HBeAg loss | 30.27 (23.96;38.24)
Peginterferon alfa-2b ^81^
Peginterferon alfa-2b ^81^ | 2 | Follow | Normalization ALT | 30.88 (25.38;37.56)
Peginterferon alfa-2b ^81^
Peginterferon alfa-2b ^81^ | 1 | | Abdominal pain | 17.00 (16.94;17.06)
Peginterferon alfa-2b ^81^
Peginterferon alfa-2b ^81^ | 1 | | Adverse effects | 75.00 (74.92;75.08)
1 | | Alopecia | 17.00 (16.94;17.06)
1 | | Anorexia | 14.00 (13.95;14.05)
1 | | Arthralgia | 14.00 (13.95;14.05)
1 | | Depression | 19.00 (18.94;19.06)
1 | | Diarrhea | 10.00 (9.95;10.05)
1 | | Discontinuation due to drug-related adverse effects | 0.43 (0.42;0.45)
1 | | Fatigue | 38.00 (37.92;38.08)
1 | | Flu-like syndrome | 54.00 (53.92;54.08)
1 | | Headache | 35.00 (34.93;35.07)
1 | | Insomnia | 7.00 (6.96;7.04)
1 | | Local reaction | 23.00 (22.93;23.07)
1 | | Loss of >10% bodyweight | 18.00 (17.94;18.06)
1 | | Myalgia | 26.00 (25.93;26.07)
1 | | Nausea | 16.00 (15.94;16.06)
1 | | Neutropenia (<1.5*109/L) | 19.00 (18.94;19.06)
1 | | Pruritus | 9.00 (8.96;9.04)
1 | | Reduction in dose of Interferon due to adverse events | 21.00 (20.94;21.06)
1 | | Thrombocytopenia (<75*109/L) | 11.00 (10.95;11.05)
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^ | 1 | End | Combined | 59.74 (52.08;68.53)
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^ | 2 | End | HBeAg loss | 47.53 (30.58;73.87)
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^ | 2 | End | Failure | 12.20 (4.04;36.80)
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^ | 2 | End | Flare | 19.97 (16.41;24.29)
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^ | 2 | End | HBeAg seroconversion | 18.52 (5.02;68.37)
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^ | 1 | End | HBV DNA loss | 9.97 (9.22;10.79)
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^ | 2 | End | Improved histology | 8.00 (3.40;18.87)
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^ | 2 | End | Mutation | 13.45 (6.14;29.45)
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^ | 2 | End | Normalization ALT | 62.18 (58.83;65.72)
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^ | 1 | End | Relapse | 15.47 (6.53;36.64)
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^ | 1 | End | Resistance | 11.81 (8.47;16.49)
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^ | 1 | End | HBsAg loss | 5.99 (5.76;6.23)
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^ | 1 | Follow | Combined | 23.72 (22.26;25.27)
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^ | 1 | Follow | Death | 1.99 (1.92;2.07)
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^ | 1 | Follow | Decompensation | 1.08 (1.06;1.09)
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^ | 2 | Follow | HBeAg loss | 32.46 (30.71;34.31)
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^ | 1 | Follow | Flare | 14.01 (12.71;15.46)
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^ | 2 | Follow | HBeAg seroconversion | 10.67 (10.35;11.00)
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^ | 1 | Follow | HBV DNA loss | 1.16 (1.14;1.18)
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^ | 1 | Follow | Improved histology | 11.02 (10.39;11.69)
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^ | 1 | Follow | Normalization ALT | 29.96 (27.71;32.41)
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^ | 1 | Follow | Relapse | 1.19 (1.17;1.21)
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^ | 2 | Follow | HBsAg loss | 6.49 (6.31;6.67)
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^ | 2 | | Alopecia | 33.19 (16.23;67.87)
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^ | 2 | | Arthralgia | 17.60 (9.59;32.31)
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^ | 2 | | Headache | 39.63 (37.03;42.43)
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^ | 1 | | Abdominal discomfort | 44.00 (43.87;44.13)
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^ | 1 | | Abdominal pain | 16.00 (15.94;16.06)
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^
1 | | Allergic rashes | 18.00 (17.90;18.10)
1 | | Anorexia | 14.00 (13.95;14.05)
1 | | Decreased neutrophil count | 2.00 (1.96;2.04)
1 | | Decreased phosphate level | 4.00 (3.95;4.05)
1 | | Depression | 18.00 (17.94;18.06)
1 | | Diarrhea | 9.00 (8.96;9.04)
1 | | Dizziness | 16.00 (15.90;16.10)
1 | | Fatigue | 36.00 (35.92;36.08)
1 | | Fever | 72.00 (71.88;72.12)
1 | | Flu-like syndrome | 63.00 (62.92;63.08)
1 | | Increased alkaline phosphatase level | 1.00 (0.97;1.03)
1 | | Increased ALT level | 16.00 (15.90;16.10)
1 | | Increased Creatine kinase level | 1.00 (0.97;1.03)
1 | | Insomnia | 13.00 (12.95;13.05)
1 | | Local erythematous reaction | 24.00 (23.89;24.11)
1 | | Local reaction | 25.00 (24.93;25.07)
1 | | Loss of >10% bodyweight | 16.00 (15.94;16.06)
1 | | Malaise | 44.00 (43.87;44.13)
1 | | Myalgia | 26.00 (25.88;26.12)
1 | | Myalgia | 28.00 (27.93;28.07)
1 | | Nausea | 9.00 (8.96;9.04)
1 | | Neutropenia (<1.5*109/L) | 22.00 (21.93;22.07)
1 | | Pruritus | 12.00 (11.95;12.05)
1 | | Reduced appetite | 24.00 (23.89;24.11)
1 | | Reduction in dose of Interferon due to adverse events | 24.00 (23.93;24.07)
1 | | Thrombocytopenia (<75*109/L) | 9.00 (8.96;9.04)
1 | | Upper respiratory tract symptoms | 74.00 (73.88;74.12)
1 | | Vomiting or diarrhea | 14.00 (13.91;14.09)
1 | | Weight loss (>10%) | 14.00 (13.91;14.09)
Telbivudine^44,72^ | 2 | End | Normalization ALT | 82.35 (77.60;87.38)
Telbivudine^44,72^
Telbivudine^44,72^ | 2 | End | Combined | 49.71 (30.50;81.01)
Telbivudine^44,72^
Telbivudine^44,72^ | 2 | End | HBeAg loss | 27.44 (19.93;37.79)
Telbivudine^44,72^
Telbivudine^44,72^ | 2 | End | HBeAg seroconversion | 25.95 (19.72;34.14)
Telbivudine^44,72^
Telbivudine^44,72^ | 2 | End | HBV DNA loss | 55.26 (46.49;65.67)
Telbivudine^44,72^
Telbivudine^44,72^ | 2 | End | Relapse | 5.00 (4.80;5.22)
Telbivudine^44,72^
Telbivudine^44,72^ | 2 | End | Resistance | 1.99 (1.94;2.05)
Telbivudine^44,72^
Telbivudine^44,72^ | 1 | | Abdominal pain | 4.02 (3.85;4.19)
Telbivudine^44,72^
Telbivudine^44,72^ | 1 | | Allergic rhinitis | 1.12 (1.10;1.13)
Telbivudine^44,72^
Telbivudine^44,72^ | 1 | | Arthralgia | 4.02 (3.85;4.19)
Telbivudine^44,72^
Telbivudine^44,72^ | 1 | | At least one adverse event | 70.42 (66.40;74.68)
Telbivudine^44,72^
Telbivudine^44,72^ | 2 | | Back pain | 4.74 (3.28;6.87)
Telbivudine^44,72^
Telbivudine^44,72^ | 2 | | Cough | 5.24 (3.63;7.56)
Telbivudine^44,72^
Telbivudine^44,72^ | 1 | | Depression | 2.48 (2.16;2.84)
Telbivudine^44,72^
Telbivudine^44,72^ | 2 | | Diarrhea | 7.36 (5.82;9.30)
Telbivudine^44,72^
Telbivudine^44,72^ | 2 | | Dizziness | 3.37 (2.61;4.36)
Telbivudine^44,72^
Telbivudine^44,72^ | 1 | | Dyspepsia | 3.26 (2.54;4.18)
Telbivudine^44,72^
1 | | Epigastric discomfort | 4.02 (3.85;4.19)
2 | | Fatigue | 8.10 (6.03;10.90)
1 | | Gastritis | 7.03 (6.65;7.43)
2 | | Headache | 8.92 (6.77;11.75)
1 | | Hepatic steatosis | 4.02 (3.85;4.19)
1 | | Hordeolum | 4.02 (3.85;4.19)
1 | | Increased Creatine phosphokinase level | 5.00 (4.87;5.14)
2 | | Influenza | 17.16 (14.26;20.64)
1 | | Malaise | 7.03 (6.65;7.43)
1 | | Mouth ulceration | 1.12 (1.10;1.13)
1 | | Myalgia | 1.99 (1.94;2.05)
2 | | Nasopharyngitis | 4.23 (3.16;5.67)
2 | | Nausea | 5.10 (4.57;5.68)
2 | | Pharyngolaryngeal pain | 5.79 (3.88;8.64)
1 | | Toothache | 4.02 (3.85;4.19)
1 | | Total adverse effect | 75.94 (69.89;82.53)
2 | | Upper abdominal pain | 7.00 (5.95;8.24)
2 | | Upper respiratory tract infection | 6.70 (4.06;11.04)
Telbivudine + Lamivudine ^72^ | 1 | | Back pain | 10.00 (9.88;10.12)
Telbivudine + Lamivudine ^72^
Telbivudine + Lamivudine ^72^ | 1 | | Depression | 5.00 (4.91;5.09)
Telbivudine + Lamivudine ^72^
Telbivudine + Lamivudine ^72^ | 1 | | Diarrhea | 5.00 (4.91;5.09)
Telbivudine + Lamivudine ^72^
Telbivudine + Lamivudine ^72^ | 1 | | Increased Creatine phosphokinase level | 5.00 (4.91;5.09)
Telbivudine + Lamivudine ^72^
Telbivudine + Lamivudine ^72^ | 1 | | Upper respiratory tract infection | 10.00 (9.88;10.12)
Telbivudine + Lamivudine ^72^
Telbivudine + Lamivudine ^72^ | 1 | End | Normalization ALT | 78.08 (74.29;82.07)
Telbivudine + Lamivudine ^72^
Telbivudine + Lamivudine ^72^ | 1 | End | Combined | 35.49 (18.71;67.30)
Telbivudine + Lamivudine ^72^
Telbivudine + Lamivudine ^72^ | 1 | End | HBeAg loss | 16.95 (15.59;18.42)
Telbivudine + Lamivudine ^72^
Telbivudine + Lamivudine ^72^ | 1 | End | HBeAg seroconversion | 15.03 (14.02;16.11)
Telbivudine + Lamivudine ^72^
Telbivudine + Lamivudine ^72^ | 1 | End | HBV DNA loss | 48.91 (44.39;53.89)
Telbivudine + Lamivudine ^72^
Telbivudine + Lamivudine ^72^ | 1 | End | Relapse | 11.94 (11.14;12.80)
1 | | At least one adverse | 70.51 (65.96;75.37)
1 | | Cough | 7.05 (3.59;13.87)
1 | | Dizziness | 7.05 (3.59;13.87)
1 | | Dyspepsia | 2.45 (2.33;2.57)
1 | | Fatigue | 7.05 (3.59;13.87)
1 | | Headache | 13.71 (7.32;25.66)
1 | | Influenza | 23.76 (15.14;37.30)
1 | | Nasopharyngitis | 7.05 (3.59;13.87)
1 | | Nausea | 4.88 (1.20;19.80)
1 | | Pharyngolaryngeal pain | 5.98 (0.99;36.31)
1 | | Upper abdominal pain | 4.88 (1.20;19.80)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^ | 11 | | HBV DNA loss | 7.18 (4.44;11.61)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^ | 7 | | HBsAg loss | 1.73 (1.46;2.06)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^ | 2 | | Mutation | 2.26 (1.50;3.39)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^ | 2 | | Flare | 12.85 (6.00;27.49)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^ | 4 | | Failure | 17.60 (11.63;26.64)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^ | 8 | | HBeAg loss | 10.15 (8.61;11.97)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^ | 8 | | HBeAg seroconversion | 7.33 (6.36;8.44)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^ | 4 | | Relapse | 3.32 (1.53;7.17)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^ | 9 | | Normalization ALT | 12.32 (9.05;16.78)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^ | 6 | | Improved histology | 23.18 (18.44;29.12)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^ | 3 | | Resistance | 32.44 (11.19;94.07)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^ | 7 | | Combined | 4.82 (3.24;7.16)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^ | 2 | | Death | 7.91 (4.73;13.21)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^ | 1 | | HBsAg seroconversion | 5.00 (4.63;5.41)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^ | 1 | | Cirrhosis | 9.97 (8.87;11.22)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^ | 1 | | Flatulence | 5.99 (5.83;6.16)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^ | 6 | | Headache | 17.23 (10.96;27.08)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^ | 1 | | Respiratory infection | 29.08 (27.13;31.17)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^ | 1 | | Abdominal distention | 6.22 (3.08;12.59)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^ | 1 | | Abnormal ALT/AST | 15.96 (14.89;17.10)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^ | 1 | | ALT> 2 than at baseline | 5.31 (3.87;7.29)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^ | 1 | | Anorexia | 5.00 (4.87;5.14)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^ | 1 | | Back pain | 7.03 (6.84;7.23)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^ | 1 | | Chest symptoms | 7.03 (6.74;7.33)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^ | 3 | | Cough | 11.45 (6.74;19.44)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^ | 1 | | Creatinine mg/dL (>2.0–3.0) | 0.30 (0.29;0.31)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^ | 2 | | Depression | 3.32 (2.29;4.82)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^ | 6 | | Diarrhea | 7.11 (3.58;14.09)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^ | 4 | | Dizziness | 7.00 (5.33;9.20)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^ | 1 | | Ear, nose, and throat | 29.58 (27.49;31.82)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^ | 2 | | Fever | 1.64 (0.92;2.94)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^ | 1 | | Hair loss | 5.00 (4.87;5.14)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^ | 2 | | Leucopenia | 4.45 (3.59;5.52)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^ | 2 | | Malaise and fatigue | 22.00 (18.42;26.28)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^ | 2 | | Muscle pain | 8.64 (7.94;9.41)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^ | 2 | | Musculoskeletal pain | 4.16 (3.31;5.23)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^ | 2 | | Nasal signs and symptoms | 6.21 (5.17;7.47)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^ | 2 | | Nausea and vomiting | 2.88 (1.66;5.00)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^ | 1 | | Nausea/vomiting | 20.09 (18.74;21.53)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^ | 2 | | Pain | 9.54 (6.75;13.47)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^ | 2 | | Rash | 5.67 (2.88;11.14)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^ | 1 | | Rheumatism | 4.02 (3.85;4.19)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^ | 1 | | Throat discomfort | 8.00 (7.68;8.34)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^ | 1 | | Viral respiratory infection | 0.90 (0.88;0.91)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^ | 1 | | >1 treatment-related event | 12.00 (11.94;12.06)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^ | 1 | | »1 adverse event | 76.71 (71.57;82.21)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^ | 1 | | Abdominal discomfort | 20.31 (17.65;23.37)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^ | 1 | | Abdominal pain and discomfort | 4.00 (3.96;4.04)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^ | 1 | | Abnormal enzymes (amylase/CPK) | 7.03 (6.74;7.33)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^ | 1 | | Abnormal liver-function | 8.00 (7.68;8.34)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^ | 1 | | ALT »2 times above base-line levels and bilirubin »2 times above baseline levels | 0.84 (0.59;1.19)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^ | 1 | | Collapse after dizziness | 0.00 (0.85;0.90)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^ | 1 | | Constipation | 4.00 (3.96;4.04)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^ | 1 | | Creatinine mg/dL (>3.0–6.0) | 0.30 (0.29;0.31)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^93,^,^94,^,^96,^,^99,^,^100,^,^103,^,^104,^,^108,^,^110,^,^112,^,^89,105^
1 | | Creatinine mg/dL (>6.0)- | 0.30 (0.29;0.31)
1 | | Creatinine mg/dL (1.5–2.0) | 0.30 (0.29;0.31)
1 | | Decreased WBCs | 0.90 (0.88;0.91)
1 | | Developing of IFN neutralizing antibodies | 0.00 (1.74;1.83)
1 | | Discontinuation due to adverse events | 1.00 (0.99;1.01)
1 | | Discontinuation due to depression | 0.00 (1.74;1.83)
3 | | Discontinuation due to adverse effects | 1.65 (0.83;3.29)
1 | | Discontinuation due to psychosis | 0.00 (1.74;1.83)
1 | | Dose reduced due to an adverse event or abnormal laboratory result | 1.00 (0.99;1.01)
1 | | Dose reduction due to depression, fatigue, hair loss, and headache | 0.00 (0.85;0.90)
3 | | Fatigue | 4.61 (2.91;7.30)
1 | | Feeding problems | 4.02 (3.85;4.19)
1 | | Gastrointestinal events | 6.00 (5.96;6.04)
1 | | Glycosuria(+1) | 3.00 (2.97;3.03)
1 | | Glycosuria(+2) | 2.00 (1.98;2.02)
1 | | Glycosuria(+3) | 3.00 (2.97;3.03)
1 | | Glycosuria(+4) | 0.30 (0.29;0.31)
1 | | Grade III or IV laboratory abnormalities in Alanine aminotransferase | 13.00 (12.92;13.08)
1 | | Grade III or IV laboratory abnormalities in Albumin | 3.00 (2.96;3.04)
1 | | Grade III or IV laboratory abnormalities in Amylase | 1.00 (0.98;1.02)
1 | | Grade III or IV laboratory abnormalities in Creatine kinase | 4.00 (3.96;4.04)
1 | | Grade III or IV laboratory abnormalities in Lipase | 7.00 (6.94;7.06)
1 | | Grade III or IV laboratory abnormalities in Platelets | 3.00 (2.96;3.04)
1 | | Grade IV abnormality in ALT | 0.84 (0.59;1.19)
1 | | Hair loss/alopecia | 4.02 (3.85;4.19)
1 | | Hematuria Obstructive or Rx required | 0.00 (0.29;0.31)
1 | | Hematuria<10 RBCs | 7.00 (6.96;7.04)
1 | | Hematuria>100 RBCs | 13.00 (12.95;13.05)
1 | | Hematuria10–100 RBCs | 10.00 (9.96;10.04)
1 | | Hypophosphatemia mg/dL (<1.0) | 0.30 (0.29;0.31)
1 | | Hypophosphatemia mg/dL (1.0–1.5) | 0.30 (0.29;0.31)
1 | | Hypophosphatemia mg/dL (1.5–<2.0) | 1.00 (0.99;1.01)
1 | | Hypophosphatemia mg/dL (2.0–2.2) | 1.00 (0.99;1.01)
1 | | Incidence of elevation of serum ALT to >5 times the ULN | 55.15 (52.17;58.29)
1 | | Infections | 0.00 (2.22;2.33)
1 | | Jaundice | 0.00 (2.22;2.33)
1 | | Liver symptoms | 4.00 (3.96;4.04)
1 | | Malaise/fatigue | 32.14 (29.57;34.92)
1 | | Marrow suppression | 0.00 (2.22;2.33)
1 | | Muscular or skeletal pain | 4.00 (3.96;4.04)
1 | | Nasopharyngitis | 1.99 (1.97;2.02)
2 | | Nausea | 7.64 (2.33;25.09)
1 | | Paresthesias | 7.00 (6.94;7.06)
1 | | Proteinuria mg/dL(Nephrotic syndrome) | 0.00 (0.29;0.31)
1 | | Proteinuria mg/dL(<100) | 10.00 (9.96;10.04)
1 | | Proteinuria mg/dL(>1000) | 0.30 (0.29;0.31)
1 | | Proteinuria mg/dL100–1000) | 7.00 (6.96;7.04)
1 | | Pruritis | 4.00 (3.96;4.04)
1 | | Sleep disorder | 4.00 (3.96;4.04)
1 | | Sleep disturbance | 4.00 (3.96;4.04)
1 | | Temperature regulation disturbance | 6.92 (5.88;8.16)
1 | | Throat and tonsil disorder | 16.95 (15.83;18.14)
1 | | Upper respiratory tract infection | 8.00 (7.79;8.23)
1 | | Upper respiratory viral infection | 4.00 (3.96;4.04)
1 | | Viral respiratory infection | 27.52 (18.01;42.07)
HBeAg-positive patients
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 4 | End | HBV DNA loss | 24.83 (15.74;39.18)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 4 | End | Normalization ALT | 59.46 (52.08;67.89)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 2 | End | Flare | 2.72 (0.96;7.71)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 4 | End | HBeAg loss | 16.53 (12.33;22.16)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 4 | End | HBeAg seroconversion | 12.35 (10.03;15.20)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 2 | End | Relapse | 8.97 (5.76;13.98)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 1 | End | HBsAg loss | 2.64 (2.49;2.80)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 1 | End | Improved histology | 51.72 (45.88;58.30)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 2 | End | Resistance | 21.64 (16.35;28.64)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 1 | End | Failure | 10.07 (8.85;11.47)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 1 | End | Mutation | 27.94 (26.86;29.06)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 1 | Followup off treatment | Normalization ALT | 38.86 (36.64;41.22)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 1 | | Insomnia | 20.91 (18.71;23.36)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 1 | | Discontinuation | 7.50 (6.97;8.07)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 1 | | Discontinuation due to adverse effects | 1.00 (0.99;1.01)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 1 | | Dose reduced due to an adverse event/ abnormal lab result | 8.49 (3.83;18.83)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 2 | | Fatigue | 3.31 (2.12;5.15)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 1 | | Flu-like syndrome | 16.95 (15.83;18.14)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 1 | | Hematuria10–100 RBCs | 13.65 (10.84;17.19)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 2 | | Pharyngitis | 30.21 (25.01;36.48)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 1 | | Proteinuria mg/dL100–1000 | 8.80 (5.82;13.29)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 1 | | Rash | 20.91 (18.71;23.36)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 1 | | Sinusitis | 15.96 (14.28;17.83)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 1 | | Any adverse event | 95.00 (94.94;95.06)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 2 | | Asthenia | 29.84 (26.48;33.62)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 1 | | Fever | 15.96 (14.28;17.83)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 3 | | Headache | 17.27 (12.27;24.29)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 1 | | Hematuria>100 RBCs | 8.46 (5.72;12.50)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 2 | | Nasopharyngitis | 5.75 (4.98;6.63)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 1 | | Reactivation of hepatitis | 1.00 (0.99;1.01)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 1 | | Serum Glucose Grade 3 abnormalities | 11.02 (10.00;12.15)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 1 | | Total adverse effect | 63.75 (59.53;68.28)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 2 | | Upper respiratory tract infection | 9.71 (8.67;10.88)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 1 | | Incidence of elevation of serum ALT to >5 times the ULN | 28.19 (20.26;39.23)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 1 | | Increases from baseline of 0.5 mg per deciliter (44 μmol per liter) or greater in the serum creatinine level | 8.00 (7.70;8.32)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 1 | | Hypophosphatemia mg/dL (<1.0) | 1.00 (0.99;1.01)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 1 | | Hypophosphatemia mg/dL (1.0–1.5) | 1.73 (0.93;3.23)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 1 | | Bacterial infection | 2.64 (2.53;2.75)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 1 | | ALT Grade 4 >10 times the ULN) | 2.64 (2.53;2.75)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 1 | | Grade 4 (>10 times the ULN) | 2.64 (2.53;2.75)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^ | 1 | | Amylase Grade3 (>2–5 times the ULN) | 2.64 (2.53;2.75)
Adefovir dipivoxil ^40,^,^42,^,^44,^,^99,100^
1 | | Grade4 (>5 times the ULN) | 2.64 (2.53;2.75)
1 | | Grade4 (>30 mg/dL; <500 mg/dL) | 2.63 (2.57;2.70)
1 | | Grade4 (4+) | 2.64 (2.53;2.75)
1 | | Cough | 3.79 (2.02;7.12)
2 | | Dizziness | 4.73 (2.29;9.80)
1 | | Malaise | 2.12 (1.30;3.45)
1 | | Epigastric discomfort | 1.49 (1.13;1.97)
1 | | Gastritis | 1.10 (1.08;1.12)
1 | | Myalgia | 2.12 (1.30;3.45)
1 | | Hordeolum | 1.10 (1.08;1.12)
3 | | Abdominal pain | 7.08 (3.35;14.95)
1 | | Hepatic steatosis | 1.47 (1.09;1.97)
1 | | Toothache | 1.47 (1.09;1.97)
1 | | Allergic rhinitis | 2.33 (1.30;4.18)
1 | | Creatinine mg/dL (1.5–2.0) | 2.51 (1.11;5.68)
1 | | Glycosuria (+1) | 1.41 (0.96;2.09)
1 | | Glycosuria (+2) | 1.41 (0.96;2.09)
1 | | Glycosuria (+3) | 1.00 (0.99;1.01)
1 | | Discontinuation due to adverse events | 2.45 (1.94;3.09)
3 | | Diarrhea | 7.24 (3.97;13.22)
3 | | Nausea | 7.22 (4.15;12.57)
1 | | Pharyngolaryngeal pain | 3.74 (2.04;6.87)
1 | | Mouth ulceration | 3.16 (1.93;5.17)
1 | | Anorexia | 6.33 (4.08;9.81)
1 | | Hypophosphatemia mg/dL (2.0–2.2) | 5.55 (4.16;7.40)
2 | | Arthralgia | 6.00 (4.69;7.67)
1 | | Gastroenteritis | 5.00 (4.67;5.36)
1 | | Infection | 5.00 (4.67;5.36)
1 | | Rhinitis | 5.00 (4.67;5.36)
1 | | AST Grade3 (>5–10 times the ULN) | 5.00 (4.67;5.36)
1 | | Upper abdominal pain | 7.42 (4.80;11.46)
3 | | Back pain | 7.96 (6.78;9.36)
2 | | Increased cough | 8.97 (6.78;11.87)
1 | | Influenza | 7.97 (6.91;9.18)
2 | | Pain | 9.86 (8.50;11.44)
1 | | Flatulence | 8.94 (7.89;10.12)
1 | | Severe (grade 3 or 4) clinical adverse events | 9.49 (8.97;10.04)
1 | | Dyspepsia | 9.97 (8.91;11.17)
1 | | Urine Glucose Grade3 | 11.02 (10.00;12.15)
1 | | Hematuria>100 RBCs | 12.37 (11.84;12.91)
1 | | Proteinuria mg/dL(<100) | 17.55 (13.60;22.64)
1 | | ALT Grade 3 (>5–10 times the ULN) | 36.97 (32.18;42.46)
Adefovir dipivoxil + Lamivudine ^43^ | 1 | End | HBV DNA loss | 35.16 (30.61;40.39)
Adefovir dipivoxil + Lamivudine ^43^
Adefovir dipivoxil + Lamivudine ^43^ | 1 | End | HBeAg loss | 15.03 (13.64;16.56)
Adefovir dipivoxil + Lamivudine ^43^
Adefovir dipivoxil + Lamivudine ^43^ | 1 | End | HBeAg seroconversion | 5.00 (4.73;5.29)
Adefovir dipivoxil + Lamivudine ^43^
Adefovir dipivoxil + Lamivudine ^43^ | 1 | End | Normalization ALT | 49.90 (43.44;57.32)
Adefovir dipivoxil + Lamivudine ^43^
Adefovir dipivoxil + Lamivudine ^43^ | 1 | End | HBsAg loss | 5.00 (4.73;5.29)
Adefovir dipivoxil + Lamivudine ^43^
Adefovir dipivoxil + Lamivudine ^43^ | 1 | | Any adverse event | 90.02 (82.84;97.82)
Adefovir dipivoxil + Lamivudine ^43^
Adefovir dipivoxil + Lamivudine ^43^ | 1 | | Asthenia | 49.90 (43.44;57.32)
Adefovir dipivoxil + Lamivudine ^43^
Adefovir dipivoxil + Lamivudine ^43^ | 1 | | Headache | 29.96 (26.45;33.95)
Adefovir dipivoxil + Lamivudine ^43^
Adefovir dipivoxil + Lamivudine ^43^ | 1 | | Pharyngitis | 5.00 (4.73;5.29)
Adefovir dipivoxil + Lamivudine ^43^
Adefovir dipivoxil + Lamivudine ^43^ | 1 | | Abdominal pain | 29.96 (26.45;33.95)
Adefovir dipivoxil + Lamivudine ^43^
Adefovir dipivoxil + Lamivudine ^43^ | 1 | | Back pain | 15.03 (13.64;16.56)
Adefovir dipivoxil + Lamivudine ^43^
Adefovir dipivoxil + Lamivudine ^43^ | 1 | | Nausea | 20.09 (17.98;22.44)
Adefovir dipivoxil + Lamivudine ^43^
Adefovir dipivoxil + Lamivudine ^43^ | 1 | | Pain | 20.09 (17.98;22.44)
Adefovir dipivoxil + Lamivudine ^43^
Adefovir dipivoxil + Lamivudine ^43^ | 1 | | Infection | 15.03 (13.64;16.56)
Adefovir dipivoxil + Lamivudine ^43^
Adefovir dipivoxil + Lamivudine ^43^ | 1 | | ALT Grade 3 (>5–10 times ULN) | 2.51 (2.41;2.62)
Adefovir dipivoxil + Lamivudine ^43^
Adefovir dipivoxil + Lamivudine ^43^ | 1 | | Insomnia | 2.51 (2.41;2.62)
Adefovir dipivoxil + Lamivudine ^43^
1 | | Rash | 2.51 (2.41;2.62)
1 | | Fever | 2.51 (2.41;2.62)
1 | | Increased cough | 2.51 (2.41;2.62)
1 | | Gastroenteritis | 2.51 (2.41;2.62)
1 | | Grade4 (>10 times the ULN) | 2.51 (2.41;2.62)
1 | | Grade4 (>5 times the ULN) | 2.51 (2.41;2.62)
1 | | Grade4 (>30 mg/dL; <500 mg/dL) | 2.51 (2.41;2.62)
1 | | Grade4 (4+) | 2.51 (2.41;2.62)
1 | | Sinusitis | 5.00 (4.73;5.29)
1 | | Arthralgia | 5.00 (4.73;5.29)
1 | | ALT Grade 4 >10 times ULN | 5.00 (4.73;5.29)
1 | | Serum glucose Grade3 abnormalities | 5.00 (4.63;5.41)
1 | | Urine Glucose Grade3 | 5.00 (4.73;5.29)
1 | | Diarrhea | 9.97 (9.18;10.84)
1 | | Rhinitis | 9.97 (9.18;10.84)
1 | | Amylase Grade3 (>2–5 ULN) | 9.97 (9.18;10.84)
1 | | Bacterial infection | 15.03 (13.64;16.56)
Entecavir ^73,^,^75,101^ | 1 | End | Improved histology | 43.51 (31.63;59.85)
Entecavir ^73,^,^75,101^
Entecavir ^73,^,^75,101^ | 2 | End | Resistance | 19.76 (7.85;49.71)
Entecavir ^73,^,^75,101^
Entecavir ^73,^,^75,101^ | 3 | End | Failure | 5.42 (1.89;15.52)
Entecavir ^73,^,^75,101^
Entecavir ^73,^,^75,101^ | 3 | End | Combined | 42.68 (26.13;69.70)
Entecavir ^73,^,^75,101^
Entecavir ^73,^,^75,101^ | 3 | End | Normalization ALT | 73.28 (62.93;85.34)
Entecavir ^73,^,^75,101^
Entecavir ^73,^,^75,101^ | 2 | End | HBeAg loss | 14.81 (6.83;32.11)
Entecavir ^73,^,^75,101^
Entecavir ^73,^,^75,101^ | 3 | End | HBeAg seroconversion | 16.98 (8.79;32.81)
Entecavir ^73,^,^75,101^
Entecavir ^73,^,^75,101^ | 3 | End | Flare | 2.08 (1.02;4.27)
Entecavir ^73,^,^75,101^
Entecavir ^73,^,^75,101^ | 3 | End | Death | 1.00 (0.98;1.02)
Entecavir ^73,^,^75,101^
Entecavir ^73,^,^75,101^ | 2 | End | HBV DNA loss | 73.20 (65.17;82.23)
Entecavir ^73,^,^75,101^
Entecavir ^73,^,^75,101^ | 2 | End | HBsAg loss | 3.74 (1.09;12.87)
Entecavir ^73,^,^75,101^
Entecavir ^73,^,^75,101^ | 1 | End | HBsAg seroconversion | 1.99 (1.96;2.03)
Entecavir ^73,^,^75,101^
Entecavir ^73,^,^75,101^ | 1 | End | Relapse | 4.02 (3.94;4.09)
Entecavir ^73,^,^75,101^
1 | End | Decompensation | 0.14 (0.14;0.15)
2 | Followup off treatment | Combined | 9.84 (4.06;23.85)
1 | Followup off treatment | Flare | 1.00 (0.98;1.02)
1 | Followup off treatment | Death | 1.00 (0.98;1.02)
1 | Followup off treatment | HBV DNA loss | 7.03 (6.89;7.17)
1 | Followup off treatment | Relapse | 1.99 (1.96;2.03)
1 | Followup off treatment | Decompensation | 0.14 (0.14;0.15)
2 | All | Any adverse event | 85.36 (82.63;88.19)
2 | All | Serious adverse events | 6.84 (3.97;11.80)
1 | All | Discontinuations because of adverse events | 1.00 (0.98;1.02)
1 | All | Discontinuation due to adverse effects | 0.14 (0.14;0.15)
1 | All | ALT >2× baseline and >5× ULN | 1.00 (0.99;1.01)
1 | All | ALT > 2× reference value and >5× ULN | 10.00 (9.97;10.03)
1 | All | Any adverse effect | 77.20 (77.17;77.23)*†
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^ | 3 | End | Normalization ALT | 46.38 (27.43;78.42)
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^ | 5 | End | HBV DNA loss | 46.97 (34.69;63.61)
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^ | 4 | End | HBeAg loss | 50.78 (33.81;76.25)
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^ | 3 | End | HBeAg seroconversion | 40.09 (20.44;78.63)
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^ | 2 | End | HBsAg loss | 6.14 (3.47;10.88)
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^ | 1 | End | Combined | 24.99 (17.81;35.07)
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^ | 1 | End | Resistance | 7.03 (6.50;7.60)
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^ | 1 | End | Improved histology | 25.03 (20.57;30.45)
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^ | 2 | End | Death | 6.83 (3.05;15.27)
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^ | 1 | End | Flare | 5.99 (5.43;6.61)
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^ | 6 | Followup off treatment | Normalization ALT | 36.49 (26.10;51.03)
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^ | 11 | Followup off treatment | HBV DNA loss | 26.97 (18.34;39.67)
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^ | 10 | Followup off treatment | HBeAg loss | 42.96 (32.25;57.23)
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^ | 5 | Followup off treatment | HBeAg seroconversion | 31.86 (19.64;51.66)
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^ | 8 | Followup off treatment | HBsAg loss | 7.41 (4.20;13.07)
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^ | 8 | Followup off treatment | Combined | 13.49 (8.41;21.64)
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^ | 3 | Followup off treatment | Resistance | 7.64 (4.46;13.08)
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^ | 3 | Followup off treatment | Relapse | 2.24 (1.72;2.91)
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^ | 2 | Followup off treatment | Death | 4.16 (2.27;7.62)
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^ | 2 | Followup off treatment | HBsAg seroconversion | 6.32 (0.66;60.79)
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^ | 2 | Followup off treatment | Improved histology | 26.91 (15.24;47.50)
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^ | 1 | Followup off treatment | Cirrhosis | 8.92 (2.86;27.81)
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^ | 1 | Followup off treatment | Failure | 25.03 (22.69;27.61)
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^ | 1 | Followup off treatment | Mutation | 0.73 (0.71;0.74)
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^ | 1 | | Abdominal discomfort and pain | 33.00 (32.89;33.11)
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^ | 1 | | Adverse effects | 75.00 (74.92;75.08)
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^
Interferon Alfa-2b ^82,^,^83,85^–^87,^,^89,^,^90,^,^94,^,^96,^,^104,105^ | 1 | | Anorexia | 47.00 (46.89;47.11)
1 | | Arthralgia | 33.00 (32.89;33.11)
1 | | Arthralgia | 8.00 (7.90;8.10)
1 | | Collapse after dizziness | 2.00 (1.97;2.03)
1 | | Depression | 4.00 (3.93;4.07)
1 | | Diarrhea | 23.00 (22.90;23.10)
1 | | Discontinuation due to depression | 3.00 (2.94;3.06)
1 | | Dizziness | 27.00 (26.90;27.10)
1 | | Dose reduction due to depression, fatigue, hair loss, headache | 11.00 (10.92;11.08)
1 | | Fatigue | 48.00 (47.82;48.18)
1 | | Fever/chills | 61.00 (60.89;61.11)
1 | | Hair loss and alopecia | 30.00 (29.90;30.10)
1 | | Headache | 67.00 (66.89;67.11)
1 | | Infections | 8.00 (7.90;8.10)
1 | | Jaundice | 4.00 (3.93;4.07)
1 | | Malaise and fatigue | 100.00 (100.00;100.00)
1 | | Marrow suppression | 8.00 (7.90;8.10)
1 | | mouth dryness | 19.00 (18.83;19.17)
1 | | Muscle pain | 57.00 (56.89;57.11)
1 | | Nausea | 12.00 (11.88;12.12)
1 | | Nausea and vomiting | 49.00 (48.89;49.11)
1 | | Discontinuation due to drug-related adverse effects | 3.00 (2.97;3.03)
1 | | Discontinuation due to psychosis | 3.00 (2.94;3.06)
1 | | Reduction in dose because of severe side effects | 8.00 (7.90;8.10)
1 | | Viral respiratory infections | 53.00 (52.89;53.11)
5 | | Discontinuation due to adverse effects | 2.91 (1.41;5.99)
1 | | Discontinuation due to neuropsychiatric disorder | 3.63 (1.93;6.80)
2 | | Reduction in dose due to adverse effects | 20.70 (18.64;22.98)
Interferon Alfa-2b + Corticosteroid ^90^ {Perez, 1990 #562,^91^–^94,^,^96,103^ | 2 | End | Combined | 39.50 (33.32;46.83)
Interferon Alfa-2b + Corticosteroid ^90^ {Perez, 1990 #562,^91^–^94,^,^96,103^
Interferon Alfa-2b + Corticosteroid ^90^ {Perez, 1990 #562,^91^–^94,^,^96,103^ | 1 | End | Death | 2.77 (2.56;3.00)
Interferon Alfa-2b + Corticosteroid ^90^ {Perez, 1990 #562,^91^–^94,^,^96,103^
Interferon Alfa-2b + Corticosteroid ^90^ {Perez, 1990 #562,^91^–^94,^,^96,103^ | 3 | End | HBsAg loss | 9.22 (6.42;13.24)
Interferon Alfa-2b + Corticosteroid ^90^ {Perez, 1990 #562,^91^–^94,^,^96,103^
Interferon Alfa-2b + Corticosteroid ^90^ {Perez, 1990 #562,^91^–^94,^,^96,103^ | 2 | End | HBV DNA loss | 37.38 (23.78;58.77)
Interferon Alfa-2b + Corticosteroid ^90^ {Perez, 1990 #562,^91^–^94,^,^96,103^
Interferon Alfa-2b + Corticosteroid ^90^ {Perez, 1990 #562,^91^–^94,^,^96,103^ | 1 | End | Resistance | 47.85 (42.56;53.80)
Interferon Alfa-2b + Corticosteroid ^90^ {Perez, 1990 #562,^91^–^94,^,^96,103^
Interferon Alfa-2b + Corticosteroid ^90^ {Perez, 1990 #562,^91^–^94,^,^96,103^ | 2 | End | HBeAg loss | 42.02 (19.39;91.04)
Interferon Alfa-2b + Corticosteroid ^90^ {Perez, 1990 #562,^91^–^94,^,^96,103^
Interferon Alfa-2b + Corticosteroid ^90^ {Perez, 1990 #562,^91^–^94,^,^96,103^ | 2 | Followup off treatment | Combined | 7.03 (2.37;20.89)
Interferon Alfa-2b + Corticosteroid ^90^ {Perez, 1990 #562,^91^–^94,^,^96,103^
Interferon Alfa-2b + Corticosteroid ^90^ {Perez, 1990 #562,^91^–^94,^,^96,103^ | 1 | Followup off treatment | Death | 5.00 (4.45;5.63)
Interferon Alfa-2b + Corticosteroid ^90^ {Perez, 1990 #562,^91^–^94,^,^96,103^
Interferon Alfa-2b + Corticosteroid ^90^ {Perez, 1990 #562,^91^–^94,^,^96,103^ | 2 | Followup off treatment | Relapse | 3.33 (2.11;5.26)
Interferon Alfa-2b + Corticosteroid ^90^ {Perez, 1990 #562,^91^–^94,^,^96,103^
Interferon Alfa-2b + Corticosteroid ^90^ {Perez, 1990 #562,^91^–^94,^,^96,103^ | 3 | Followup off treatment | HBsAg loss | 17.25 (5.51;54.07)
6 | Followup off treatment | HBV DNA loss | 24.44 (16.31;36.63)
2 | Followup off treatment | Resistance | 18.36 (9.25;36.45)
1 | Followup off treatment | Cirrhosis | 9.97 (9.04;11.00)
3 | Followup off treatment | Normalization ALT | 35.77 (20.48;62.47)
3 | Followup off treatment | HBeAg loss | 45.64 (33.35;62.46)
2 | Followup off treatment | HBeAg seroconversion | 51.10 (44.58;58.58)
1 | | Reduction in dose because of severe side effects | 8.00 (7.90;8.10)
1 | | Leucopenia | 20.00 (19.79;20.21)
1 | | Discontinuation due to adverse effects | 2.94 (2.87;3.01)
1 | | Reduction in dose due to adverse effects | 12.00 (11.86;12.14)
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^ | 3 | End | Mutation | 3.30 (1.55;7.06)
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^ | 1 | End | HBsAg loss | 5.99 (5.75;6.24)
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^ | 4 | End | HBeAg seroconversion | 31.30 (13.42;73.00)
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^ | 3 | End | Failure | 13.17 (8.74;19.85)
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^ | 4 | End | HBeAg loss | 38.85 (21.64;69.72)
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^ | 4 | End | Normalization ALT | 44.07 (22.58;86.02)
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^ | 6 | End | HBV DNA loss | 59.03 (41.91;83.15)
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^ | 5 | End | Improved histology | 36.77 (31.13;43.43)
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^ | 1 | End | Flare | 1.52 (1.46;1.58)
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^ | 1 | End | Relapse | 4.02 (3.86;4.18)
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^ | 2 | End | Combined | 55.02 (31.63;95.72)
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^ | 1 | End | Resistance | 57.02 (50.92;63.85)
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^ | 1 | Followup off treatment | Mutation | 0.66 (0.66;0.67)
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^ | 2 | Followup off treatment | HBsAg loss | 2.54 (0.52;12.36)
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^ | 6 | Followup off treatment | HBeAg seroconversion | 35.15 (20.28;60.93)
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^ | 2 | Followup off treatment | Failure | 21.96 (19.92;24.22)
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^ | 5 | Followup off treatment | HBeAg loss | 39.96 (29.41;54.30)
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^ | 6 | Followup off treatment | Normalization ALT | 61.61 (50.09;75.77)
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^ | 7 | Followup off treatment | HBV DNA loss | 49.14 (28.67;84.21)
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^ | 1 | Followup off treatment | Improved histology | 27.94 (26.07;29.94)
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^ | 1 | Followup off treatment | Flare | 5.00 (4.72;5.31)
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^ | 2 | Followup off treatment | Relapse | 6.68 (3.57;12.50)
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^ | 2 | Followup off treatment | Combined | 32.39 (27.06;38.76)
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^ | 1 | | ALT> 2 than at baseline | 1.26 (0.81;1.96)
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^
Interferon Alfa-2b + Lamivudine ^47,65^–^69,^,^79,^,^80,104^ | 4 | | Discontinuation due AE | 4.77 (3.34;6.81)
1 | | Arthralgia | 11.94 (11.30;12.62)
1 | | Dizziness | 11.94 (11.30;12.62)
1 | | Abnormal enzymes | 12.94 (12.24;13.67)
1 | | Abdominal discomfort | 14.01 (13.26;14.81)
1 | | Abnormal ALT/AST | 15.96 (15.10;16.87)
1 | | Pain | 15.96 (15.10;16.87)
1 | | Musculoskeletal pain | 15.96 (15.10;16.87)
4 | | Diarrhea | 14.08 (7.59;26.10)
1 | | Decreased WBCs | 25.03 (23.35;26.82)
1 | | Rheumatism | 25.03 (23.35;26.82)
2 | | Depression | 11.35 (1.52;84.71)
1 | | Feeding problems | 29.96 (27.57;32.56)
2 | | Viral respiratory in | 38.48 (34.75;42.60)
1 | | Anorexia | 38.86 (36.26;41.65)
1 | | Hair loss and alopecia | 38.86 (36.26;41.65)
1 | | Nausea and vomiting | 42.95 (39.52;46.67)
2 | | Muscle pain | 46.53 (43.87;49.34)
1 | | Nausea/vomiting | 59.15 (54.43;64.27)
1 | | Fever/chills | 60.95 (56.87;65.32)
4 | | Headache | 44.65 (43.37;45.97)
1 | | Malaise and fatigue | 87.36 (82.65;92.34)
1 | | Malaise/fatigue | 94.63 (90.78;98.65)
2 | | Fever | 94.63 (90.78;98.65)
3 | | Albumin: 2.0–2.4 g/d | 3.00 (2.89;3.12)
2 | | Influenza-like symptoms | 64.18 (58.99;69.82)
Interferon Alfa-2b + Placebo ^67,93^ | 1 | End | HBeAg loss | 83.10 (76.83;89.87)
Interferon Alfa-2b + Placebo ^67,93^
Interferon Alfa-2b + Placebo ^67,93^ | 1 | End | HBV DNA loss | 83.10 (76.83;89.87)
Interferon Alfa-2b + Placebo ^67,93^
Interferon Alfa-2b + Placebo ^67,93^ | 1 | End | Normalization ALT | 83.93 (77.60;90.78)
Interferon Alfa-2b + Placebo ^67,93^
Interferon Alfa-2b + Placebo ^67,93^ | 1 | End | HBeAg seroconversion | 92.76 (87.46;98.38)
Interferon Alfa-2b + Placebo ^67,93^
Interferon Alfa-2b + Placebo ^67,93^ | 1 | Followup off treatment | Mutation | 0.73 (0.71;0.74)
Interferon Alfa-2b + Placebo ^67,93^
Interferon Alfa-2b + Placebo ^67,93^ | 1 | Followup off treatment | Failure | 25.03 (22.69;27.61)
Interferon Alfa-2b + Placebo ^67,93^
Interferon Alfa-2b + Placebo ^67,93^ | 1 | Followup off treatment | Improved histology | 35.87 (31.89;40.35)
Interferon Alfa-2b + Placebo ^67,93^
Interferon Alfa-2b + Placebo ^67,93^ | 1 | Followup off treatment | HBeAg loss | 75.19 (65.55;86.25)
Interferon Alfa-2b + Placebo ^67,93^
Interferon Alfa-2b + Placebo ^67,93^ | 1 | Followup off treatment | HBV DNA loss | 75.19 (66.85;84.57)
Interferon Alfa-2b + Placebo ^67,93^
Interferon Alfa-2b + Placebo ^67,93^ | 1 | Followup off treatment | Normalization ALT | 75.94 (68.86;83.76)
Interferon Alfa-2b + Placebo ^67,93^
Interferon Alfa-2b + Placebo ^67,93^ | 1 | Followup off treatment | HBeAg seroconversion | 92.76 (88.98;96.70)
Interferon Alfa-2b + Placebo ^67,93^
Interferon Alfa-2b + Placebo ^67,93^ | 1 | Followup off treatment | Combined | 8.67 (2.95;25.46)
Interferon Alfa-2b + Placebo ^67,93^
Interferon Alfa-2b + Placebo ^67,93^ | 1 | | Discontinuation due to adverse effects | 0.71 (0.70;0.73)
Interferon Alfa-2b + Placebo ^67,93^
1 | | Hepatitis flares (ALT levels >500 IU/l and >2′ baseline) | 9.00 (8.93;9.07)
1 | | Hepatitis flares (ALT levels >500 IU/l and >2′ baseline) | 11.00 (10.93;11.07)
1 | | Diarrhea | 23.00 (22.90;23.10)
1 | | Dizziness | 27.00 (26.90;27.10)
1 | | Hair loss and alopecia | 30.00 (29.90;30.10)
1 | | Abdominal discomfort and pain | 33.00 (32.89;33.11)
1 | | Arthralgia | 33.00 (32.89;33.11)
1 | | Anorexia | 47.00 (46.89;47.11)
1 | | Nausea and vomiting | 49.00 (48.89;49.11)
1 | | Viral respiratory infections | 53.00 (52.89;53.11)
1 | | Muscle pain | 57.00 (56.89;57.11)
1 | | Fever/chills | 61.00 (60.89;61.11)
1 | | Headache | 67.00 (66.89;67.11)
1 | | Malaise and fatigue | 100.00 (100.00;100.00)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 12 | End | HBeAg loss | 19.08 (11.82;30.78)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 15 | End | HBeAg seroconversion | 15.42 (9.99;23.80)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 11 | End | Improved histology | 30.76 (22.17;42.67)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 11 | End | Failure | 10.04 (7.65;13.18)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 17 | End | HBV DNA loss | 43.86 (32.37;59.44)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 15 | End | Normalization ALT | 38.41 (25.65;57.51)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 4 | End | Resistance | 38.06 (27.41;52.85)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 4 | End | HBsAg loss | 1.99 (1.29;3.07)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 5 | End | Flare | 7.74 (5.84;10.27)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 3 | End | Death | 1.00 (0.99;1.01)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 8 | End | Combined | 27.95 (19.58;39.89)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 5 | End | Relapse | 12.62 (5.93;26.86)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | End | Decompensation | 0.14 (0.14;0.14)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | End | HBsAg seroconversion | 5.00 (4.81;5.20)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 6 | End | Mutation | 13.45 (6.59;27.45)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 7 | Followup off treatment | HBeAg loss | 32.22 (26.08;39.81)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 7 | Followup off treatment | HBeAg seroconversion | 24.49 (14.88;40.31)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 2 | Followup off treatment | Improved histology | 34.12 (32.73;35.57)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 2 | Followup off treatment | Failure | 11.94 (11.04;12.92)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 5 | Followup off treatment | HBV DNA loss | 9.30 (4.83;17.91)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 5 | Followup off treatment | Normalization ALT | 39.26 (23.18;66.48)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 3 | Followup off treatment | HBsAg loss | 1.56 (0.80;3.05)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 3 | Followup off treatment | Flare | 4.82 (1.96;11.90)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 3 | Followup off treatment | Death | 1.00 (0.99;1.01)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 6 | Followup off treatment | Combined | 9.89 (4.83;20.26)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 4 | Followup off treatment | Relapse | 14.06 (4.72;41.86)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 2 | Followup off treatment | Decompensation | 2.00 (1.15;3.48)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | Followup off treatment | Mutation | 23.00 (21.51;24.59)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 3 | | >1 Reported adverse | 47.41 (31.02;72.47)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | >1 Reported serious AE | 1.99 (1.97;2.02)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 4 | | Abdominal discomfort | 8.02 (4.81;13.38)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | Abdominal discomfort or pain | 15.26 (12.66;18.39)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | Abdominal distention | 8.00 (7.82;8.20)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | Abdominal pain | 26.05 (23.00;29.51)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | Abnormal ALT/AST | 17.99 (17.26;18.76)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | Abnormal enzymes (amylase/CPK) | 15.96 (15.31;16.64)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 2 | | Abnormal liver function tests | 7.04 (4.30;11.53)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | Acne and folliculitis | 3.66 (2.79;4.81)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | Albumin: 2.0–2.4 g/d | 3.00 (2.89;3.12)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | Allergic rashes | 1.99 (1.92;2.07)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 2 | | Alopecia | 2.51 (1.98;3.19)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | ALT > 2× reference value and >5× ULN | 5.00 (4.91;5.10)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | ALT >2× baseline and >5× ULN | 16.95 (16.29;17.62)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | ALT »2 times above base-line levels | 26.05 (24.09;28.17)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 2 | | ALT> 2 than at baseline and >500U/l | 3.02 (1.57;5.80)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | ALT »3 times above base-line levels | 15.17 (6.66;34.54)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | ALT Grade 3 (>5–10 times the ULN) | 2.64 (2.53;2.75)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | ALT Grade 4 >10 times the ULN) | 15.96 (14.28;17.83)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | Amylase >2× upper limit of normal | 3.66 (2.79;4.81)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | Amylase Grade3 (>2–5 times the ULN) | 15.96 (14.28;17.83)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | Amylase: value 3.1 to ten times the baseline value and >10 times the baseline value | 1.00 (0.98;1.02)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | Anorexia | 5.00 (4.87;5.14)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | Any adverse effect | 66.11 (41.30;105.81)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 3 | | Any adverse event | 36.11 (24.98;52.19)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 4 | | Arthralgia | 5.74 (4.53;7.27)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | AST Grade3 (>5–10 times the ULN) | 5.00 (4.67;5.36)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | Asthenia | 32.14 (27.98;36.91)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | At least one adverse event | 5.00 (4.93;5.07)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | At least one adverse effect | 68.03 (61.68;75.04)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 2 | | Back pain | 4.77 (3.18;7.15)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | Bacterial infection | 2.64 (2.53;2.75)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | Chest symptoms | 2.45 (1.94;3.09)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 2 | | Constipation | 3.83 (2.91;5.05)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 5 | | Cough | 14.63 (10.43;20.53)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | CPK >5× upper limit | 4.74 (3.21;7.01)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | Creatine kinase: value seven to 9.9 times the baseline value and at least ten times the baseline value | 7.03 (6.63;7.45)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | Decreased appetite | 1.99 (1.97;2.02)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | Decreased neutrophil count | 1.00 (0.98;1.02)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | Decreased phosphate level | 1.99 (1.92;2.07)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | Decreased WBCs | 1.00 (0.99;1.01)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 4 | | Depression | 4.02 (2.47;6.53)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 12 | | Diarrhea | 9.44 (7.31;12.18)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 7 | | Discontinuation due to adverse effect | 3.76 (2.61;5.43)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 8 | | Dizziness | 5.16 (4.55;5.87)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 3 | | Dyspepsia | 6.26 (4.98;7.86)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | Ear, nose, and throat infection | 21.33 (19.20;23.69)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | Dose modification due to adverse effects | 0.18 (0.18;0.19)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | Dose modification due to laboratory abnormality: Alanine aminotransferase elevation, neutropenia, and thrombocytopenia | 0.18 (0.18;0.19)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | Eczema | 3.66 (2.79;4.81)
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^
Lamivudine^43,^,^47,^,^48,^,^50,^,^53,^,^55,^,^72,^,^104,107^–^112^ | 1 | | Events of the hepatobiliary tract and pancreas | 4.60 (2.00;10.57)
4 | | Fatigue | 9.03 (6.36;12.82)
1 | | Feeding problems | 1.99 (1.97;2.02)
4 | | Fever | 5.89 (5.16;6.71)
1 | | Fever/chills | 7.03 (6.74;7.33)
1 | | Gastroenteritis | 15.96 (14.28;17.83)
1 | | Gastrointestinal events | 9.58 (7.78;11.81)
1 | | Grade III abnormality in ALT | 14.14 (7.12;28.07)
1 | | Grade III or IV lab abnormalities in alanine aminotransferase | 9.97 (9.41;10.58)
1 | | Grade III or IV laboratory abnormalities in Albumin | 0.70 (0.69;0.72)
1 | | Grade III or IV laboratory abnormalities in amylase | 0.70 (0.69;0.72)
1 | | Grade III or IV laboratory abnormalities in creatine kinase | 9.00 (8.94;9.06)
1 | | Grade III or IV laboratory abnormalities in lipase | 9.00 (8.94;9.06)
1 | | Grade III or IV laboratory abnormalities in platelets | 0.70 (0.69;0.72)
1 | | Grade IV abnormality in ALT | 1.46 (0.35;6.03)
1 | | Grade 4 (>10 times the ULN) | 11.02 (10.00;12.15)
1 | | Grade 4 (>30 mg/dL; <500 mg/dL) | 2.64 (2.53;2.75)
1 | | Grade 4 (4+) | 2.64 (2.53;2.75)
1 | | Grade 4 (>5 times the ULN) | 2.64 (2.53;2.75)
1 | | Hair loss | 1.99 (1.97;2.02)
1 | | Hair loss and alopecia | 9.97 (9.57;10.40)
1 | | Hair loss or alopecia | 1.99 (1.97;2.02)
13 | | Headache | 11.93 (9.48;15.01)
1 | | Hypoglycemia | 3.65 (3.06;4.36)
1 | | Increased alkaline phosphatase level | 2.00 (1.96;2.04)
1 | | Increased ALT level | 24.00 (23.89;24.11)
1 | | Increased cough | 15.96 (14.28;17.83)
2 | | Increased Creatine phosphokinase level | 4.16 (2.49;6.94)
1 | | Infection | 5.00 (4.67;5.36)
1 | | Influenza | 20.91 (19.33;22.61)
3 | | Influenza-like symptoms | 17.27 (14.63;20.40)
2 | | Insomnia | 6.46 (5.30;7.87)
1 | | Leucopenia | 5.00 (4.98;5.02)
1 | | Lipase: value 2.6–5 times ULNand >5 times the upper limit of normal | 3.00 (2.96;3.04)
1 | | Liver symptoms | 5.00 (4.98;5.02)
1 | | Local erythematous reaction | 1.00 (0.97;1.03)
1 | | Malaise | 14.00 (13.91;14.09)
3 | | Malaise and fatigue | 17.98 (14.62;22.12)
4 | | Malaise or fatigue | 18.47 (12.74;26.78)
6 | | Muscle pain | 4.79 (2.87;8.00)
3 | | Musculoskeletal pain | 4.77 (2.43;9.36)
2 | | Nasal signs and symptoms | 8.93 (7.83;10.18)
1 | | Nasopharyngitis | 5.00 (4.76;5.25)
3 | | Nausea | 3.96 (3.07;5.12)
4 | | Nausea and vomiting | 8.13 (6.08;10.86)
5 | | Nausea or vomiting | 8.77 (5.52;13.94)
1 | | Neurological events | 6.94 (6.04;7.98)
2 | | Pain | 4.49 (2.69;7.51)
1 | | Paresthesias | 3.00 (2.89;3.12)
1 | | Pharyngitis | 32.14 (27.98;36.91)
1 | | Pharyngolaryngeal pain | 15.96 (14.76;17.26)
1 | | Pigmentary skin disorders | 3.66 (2.79;4.81)
1 | | Platelets: value of 20 000–49 000/mm3 and less than 20 000/mm3 | 3.00 (2.96;3.04)
1 | | Pruritis | 5.00 (4.91;5.10)
1 | | Pyrexia | 4.02 (3.96;4.07)
4 | | Rash | 7.45 (6.16;9.01)
1 | | Reduced appetite | 1.00 (0.98;1.02)
1 | | Respiratory infection | 35.16 (33.81;36.57)
1 | | Rheumatism | 5.00 (4.87;5.14)
1 | | Rhinitis | 26.05 (23.00;29.51)
1 | | Severe Myalgia | 1.19 (1.14;1.23)
1 | | Serum glucose Grade3 (30–39 mg/dL; 251–500 mg/dL) | 15.96 (14.28;17.83)
1 | | Sinusitis | 26.05 (23.00;29.51)
2 | | Skin rash | 4.84 (3.37;6.97)
1 | | Sleep disorder | 7.03 (6.63;7.45)
1 | | Sleep disturbance | 5.00 (4.91;5.10)
1 | | Sore throat | 7.03 (6.84;7.23)
1 | | Temperature regulation disturbance | 8.94 (8.11;9.84)
1 | | Throat and tonsil discomfort/pain | 22.53 (21.82;23.27)
1 | | Throat discomfort or pain | 14.37 (12.76;16.18)
2 | | Upper abdominal pain | 5.63 (4.89;6.49)
1 | | Upper respiratory tract infection | 6.53 (4.72;9.03)
1 | | Upper respiratory tract symptoms | 38.00 (37.87;38.13)
1 | | Upper respiratory viral infection | 5.00 (4.98;5.02)
1 | | Urine Glucose Grade3 (3+) | 21.00 (20.83;21.17)
1 | | Vertigo | 3.66 (2.79;4.81)
1 | | Viral respiratory infection | 27.70 (25.30;30.32)
1 | | Viral respiratory infections (multiple) | 9.48 (3.53;25.46)
1 | | Vomiting or diarrhea | 6.00 (5.94;6.06)
1 | | Weight loss (>10%) | 2.00 (1.96;2.04)
1 | | Withdrawal due to side effects | 1.35 (1.32;1.39)
Peginterferon alfa-2a ^56,116^ | 1 | End | HBeAg loss | 29.96 (28.74;31.24)
Peginterferon alfa-2a ^56,116^
Peginterferon alfa-2a ^56,116^ | 1 | End | HBeAg seroconversion | 27.11 (26.01;28.26)
Peginterferon alfa-2a ^56,116^
Peginterferon alfa-2a ^56,116^ | 1 | End | Normalization ALT | 38.86 (37.28;40.51)
Peginterferon alfa-2a ^56,116^
Peginterferon alfa-2a ^56,116^ | 1 | End | Combined | 9.97 (9.70;10.26)
Peginterferon alfa-2a ^56,116^
Peginterferon alfa-2a ^56,116^ | 1 | End | HBV DNA loss | 25.03 (24.01;26.09)
Peginterferon alfa-2a ^56,116^
Peginterferon alfa-2a ^56,116^ | 1 | End | Flare | 5.00 (4.93;5.07)
Peginterferon alfa-2a ^56,116^
Peginterferon alfa-2a ^56,116^ | 1 | End | Mutation | 0.18 (0.18;0.19)
Peginterferon alfa-2a ^56,116^
Peginterferon alfa-2a ^56,116^ | 2 | Follow | HBeAg loss | 33.60 (31.77;35.53)
Peginterferon alfa-2a ^56,116^
Peginterferon alfa-2a ^56,116^ | 2 | Follow | HBeAg seroconversion | 31.98 (29.91;34.20)
Peginterferon alfa-2a ^56,116^
Peginterferon alfa-2a ^56,116^ | 2 | Follow | Normalization ALT | 37.26 (34.12;40.70)
Peginterferon alfa-2a ^56,116^
Peginterferon alfa-2a ^56,116^ | 2 | Follow | Combined | 23.88 (21.65;26.34)
Peginterferon alfa-2a ^56,116^
Peginterferon alfa-2a ^56,116^ | 1 | Follow | HBV DNA loss | 14.01 (13.63;14.41)
Peginterferon alfa-2a ^56,116^
Peginterferon alfa-2a ^56,116^ | 1 | Follow | Improved histology | 38.09 (36.54;39.71)
Peginterferon alfa-2a ^56,116^
Peginterferon alfa-2a ^56,116^ | 1 | Follow | Death | 0.18 (0.18;0.19)
Peginterferon alfa-2a ^56,116^
Peginterferon alfa-2a ^56,116^ | 1 | | Discontinuation due to AE | 3.00 (2.96;3.05)
Peginterferon alfa-2a ^56,116^
Peginterferon alfa-2a ^56,116^ | 1 | | >1 Reported serious AE | 4.02 (3.96;4.07)
Peginterferon alfa-2a ^56,116^
Peginterferon alfa-2a ^56,116^ | 2 | | Cough | 8.04 (6.56;9.84)
Peginterferon alfa-2a ^56,116^
Peginterferon alfa-2a ^56,116^ | 1 | | Dyspepsia | 5.00 (4.93;5.07)
Peginterferon alfa-2a ^56,116^
Peginterferon alfa-2a ^56,116^ | 1 | | Depression | 5.00 (4.93;5.07)
Peginterferon alfa-2a ^56,116^
Peginterferon alfa-2a ^56,116^ | 1 | | Sore throat | 5.99 (5.91;6.07)
Peginterferon alfa-2a ^56,116^
Peginterferon alfa-2a ^56,116^ | 1 | | Gingival bleeding | 5.99 (5.91;6.07)
1 | | Dose modification due to adverse effects | 7.03 (6.84;7.23)
| | Dose modification due to laboratory abnormality: Alanine aminotransferase elevation, Neutropenia, and thrombocytopenia | 36.97 (35.46;38.54)
2 | | Insomnia | 12.39 (9.30;16.52)
1 | | Rigors | 7.03 (6.84;7.23)
1 | | Upper abdominal pain | 7.03 (6.84;7.23)
1 | | Upper respiratory tract infection | 13.35 (9.25;19.26)
1 | | Anorexia | 13.96 (9.68;20.11)
2 | | Diarrhea | 12.15 (9.75;15.15)
2 | | Dizziness | 14.19 (11.26;17.89)
2 | | Nausea | 12.45 (10.30;15.05)
1 | | Injection-site reaction | 9.03 (8.78;9.28)
1 | | Arthralgia | 9.03 (8.78;9.28)
1 | | Rash | 9.97 (9.70;10.26)
1 | | Pruritus | 9.97 (9.70;10.26)
1 | | Decreased appetite | 15.03 (14.62;15.45)
2 | | Alopecia | 26.31 (21.71;31.89)
2 | | Fatigue | 28.96 (24.23;34.61)
2 | | Myalgia | 35.59 (30.05;42.15)
2 | | Headache | 38.55 (32.46;45.78)
2 | | Pyrexia | 56.61 (50.87;63.00)
1 | | >1 reported AE | 89.12 (86.69;91.63)
Peginterferon alfa-2a+Lamivudine ^56^ | 1 | End | HBeAg seroconversion | 24.05 (23.07;25.07)
Peginterferon alfa-2a+Lamivudine ^56^
Peginterferon alfa-2a+Lamivudine ^56^ | 1 | End | HBeAg loss | 27.11 (26.01;28.26)
Peginterferon alfa-2a+Lamivudine ^56^
Peginterferon alfa-2a+Lamivudine ^56^ | 1 | End | HBV DNA loss | 68.72 (65.92;71.64)
Peginterferon alfa-2a+Lamivudine ^56^
Peginterferon alfa-2a+Lamivudine ^56^ | 1 | End | Normalization ALT | 46.06 (44.19;48.02)
Peginterferon alfa-2a+Lamivudine ^56^
Peginterferon alfa-2a+Lamivudine ^56^ | 1 | End | Combined | 15.03 (14.62;15.45)
Peginterferon alfa-2a+Lamivudine ^56^
Peginterferon alfa-2a+Lamivudine ^56^ | 1 | End | Flare | 5.99 (5.91;6.07)
Peginterferon alfa-2a+Lamivudine ^56^
Peginterferon alfa-2a+Lamivudine ^56^ | 1 | End | Mutation | 3.00 (2.96;3.05)
Peginterferon alfa-2a+Lamivudine ^56^
Peginterferon alfa-2a+Lamivudine ^56^ | 1 | Follow | Death | 1.00 (0.99;1.01)
Peginterferon alfa-2a+Lamivudine ^56^
Peginterferon alfa-2a+Lamivudine ^56^ | 1 | Follow | HBV DNA loss | 14.01 (13.63;14.41)
Peginterferon alfa-2a+Lamivudine ^56^
Peginterferon alfa-2a+Lamivudine ^56^ | 1 | Follow | Combined | 20.91 (20.33;21.49)
Peginterferon alfa-2a+Lamivudine ^56^
Peginterferon alfa-2a+Lamivudine ^56^ | 1 | Follow | HBeAg seroconversion | 27.11 (26.01;28.26)
Peginterferon alfa-2a+Lamivudine ^56^
Peginterferon alfa-2a+Lamivudine ^56^ | 1 | Follow | HBeAg loss | 27.94 (26.80;29.12)
Peginterferon alfa-2a+Lamivudine ^56^
Peginterferon alfa-2a+Lamivudine ^56^ | 1 | Follow | Normalization ALT | 38.86 (37.28;40.51)
Peginterferon alfa-2a+Lamivudine ^56^
Peginterferon alfa-2a+Lamivudine ^56^ | 1 | Follow | Improved histology | 40.85 (39.19;42.59)
Peginterferon alfa-2a+Lamivudine ^56^
Peginterferon alfa-2a+Lamivudine ^56^ | 1 | | ≥1 Reported adverse event | 89.00 (88.96;89.04)
Peginterferon alfa-2a+Lamivudine ^56^
Peginterferon alfa-2a+Lamivudine ^56^ | 1 | | ≥1 Reported serious adverse event | 6.00 (5.97;6.03)
Peginterferon alfa-2a+Lamivudine ^56^
Peginterferon alfa-2a+Lamivudine ^56^ | 1 | | Alopecia | 29.00 (28.95;29.05)
Peginterferon alfa-2a+Lamivudine ^56^
Peginterferon alfa-2a+Lamivudine ^56^ | 1 | | Arthralgia | 9.00 (8.97;9.03)
Peginterferon alfa-2a+Lamivudine ^56^
Peginterferon alfa-2a+Lamivudine ^56^ | 1 | | Cough | 7.00 (6.97;7.03)
Peginterferon alfa-2a+Lamivudine ^56^
Peginterferon alfa-2a+Lamivudine ^56^ | 1 | | Decreased appetite | 13.00 (12.96;13.04)
Peginterferon alfa-2a+Lamivudine ^56^
1 | | Depression | 6.00 (5.97;6.03)
1 | | Diarrhea | 10.00 (9.96;10.04)
1 | | Discontinuation due to adverse effects | 4.00 (3.98;4.02)
1 | | Dizziness | 12.00 (11.96;12.04)
1 | | Dose modification due to adverse effects | 8.00 (7.97;8.03)
1 | | Dose modification due to Laboratory abnormality: Alanine aminotransferase elevation, Neutropenia, and thrombocytopenia | 38.00 (37.94;38.06)
1 | | Dyspepsia | 2.00 (1.98;2.02)
1 | | Fatigue | 37.00 (36.94;37.06)
1 | | Gingival bleeding | 6.00 (5.97;6.03)
1 | | Headache | 30.00 (29.95;30.05)
1 | | Injection-site reaction | 6.00 (5.97;6.03)
1 | | Insomnia | 8.00 (7.97;8.03)
1 | | Myalgia | 28.00 (27.95;28.05)
1 | | Nausea | 10.00 (9.96;10.04)
1 | | Pruritus | 10.00 (9.96;10.04)
1 | | Pyrexia | 55.00 (54.94;55.06)
1 | | Rash | 8.00 (7.97;8.03)
1 | | Rigors | 10.00 (9.96;10.04)
1 | | Sore throat | 8.00 (7.97;8.03)
1 | | Upper abdominal pain | 5.00 (4.97;5.03)
1 | | Upper respiratory tract infection | 6.00 (5.97;6.03)
Peginterferon alfa-2b ^81^ | 1 | End | Mutation | 0.32 (0.31;0.33)
Peginterferon alfa-2b ^81^
Peginterferon alfa-2b ^81^ | 1 | End | HBeAg seroconversion | 8.71 (1.91;39.80)
Peginterferon alfa-2b ^81^
Peginterferon alfa-2b ^81^ | 1 | End | Failure | 7.50 (2.20;25.53)
Peginterferon alfa-2b ^81^
Peginterferon alfa-2b ^81^ | 1 | End | HBsAg loss | 5.00 (4.81;5.20)
Peginterferon alfa-2b ^81^
Peginterferon alfa-2b ^81^ | 1 | End | Improved histology | 20.09 (18.94;21.30)
Peginterferon alfa-2b ^81^
Peginterferon alfa-2b ^81^ | 1 | End | Resistance | 14.51 (13.55;15.54)
Peginterferon alfa-2b ^81^
Peginterferon alfa-2b ^81^ | 1 | End | Flare | 24.05 (22.67;25.50)
Peginterferon alfa-2b ^81^
Peginterferon alfa-2b ^81^ | 1 | End | HBeAg loss | 26.05 (24.56;27.63)
Peginterferon alfa-2b ^81^
Peginterferon alfa-2b ^81^ | 1 | End | Normalization ALT | 29.96 (27.71;32.41)
Peginterferon alfa-2b ^81^
Peginterferon alfa-2b ^81^ | 1 | Follow | HBsAg seroconversion | 0.44 (0.43;0.45)
Peginterferon alfa-2b ^81^
Peginterferon alfa-2b ^81^ | 2 | Follow | HBeAg seroconversion | 14.01 (4.38;44.82)
Peginterferon alfa-2b ^81^
Peginterferon alfa-2b ^81^ | 2 | Follow | HBsAg loss | 6.49 (5.55;7.59)
Peginterferon alfa-2b ^81^
Peginterferon alfa-2b ^81^ | 1 | Follow | Improved histology | 8.00 (7.70;8.32)
Peginterferon alfa-2b ^81^
Peginterferon alfa-2b ^81^ | 1 | Follow | Combined | 16.95 (15.98;17.97)
Peginterferon alfa-2b ^81^
Peginterferon alfa-2b ^81^ | 2 | Follow | HBeAg loss | 30.27 (23.96;38.24)
Peginterferon alfa-2b ^81^
Peginterferon alfa-2b ^81^ | 2 | Follow | Normalization ALT | 30.88 (25.38;37.56)
Peginterferon alfa-2b ^81^
Peginterferon alfa-2b ^81^ | 1 | | Abdominal pain | 17.00 (16.94;17.06)
Peginterferon alfa-2b ^81^
Peginterferon alfa-2b ^81^ | 1 | | Adverse effects | 75.00 (74.92;75.08)
1 | | Alopecia | 17.00 (16.94;17.06)
1 | | Anorexia | 14.00 (13.95;14.05)
1 | | Arthralgia | 14.00 (13.95;14.05)
1 | | Depression | 19.00 (18.94;19.06)
1 | | Diarrhea | 10.00 (9.95;10.05)
1 | | Discontinuation due to drug-related adverse effects | 0.43 (0.42;0.45)
1 | | Fatigue | 38.00 (37.92;38.08)
1 | | Flu-like syndrome | 54.00 (53.92;54.08)
1 | | Headache | 35.00 (34.93;35.07)
1 | | Insomnia | 7.00 (6.96;7.04)
1 | | Local reaction | 23.00 (22.93;23.07)
1 | | Loss of >10% bodyweight | 18.00 (17.94;18.06)
1 | | Myalgia | 26.00 (25.93;26.07)
1 | | Nausea | 16.00 (15.94;16.06)
1 | | Neutropenia (<1.5*109/L) | 19.00 (18.94;19.06)
1 | | Pruritus | 9.00 (8.96;9.04)
1 | | Reduction in dose of Interferon due to adverse events | 21.00 (20.94;21.06)
1 | | Thrombocytopenia (<75*109/L) | 11.00 (10.95;11.05)
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^ | 1 | End | Combined | 59.74 (52.08;68.53)
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^ | 2 | End | HBeAg loss | 47.53 (30.58;73.87)
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^ | 2 | End | Failure | 12.20 (4.04;36.80)
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^ | 2 | End | Flare | 19.97 (16.41;24.29)
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^ | 2 | End | HBeAg seroconversion | 18.52 (5.02;68.37)
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^ | 1 | End | HBV DNA loss | 9.97 (9.22;10.79)
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^ | 2 | End | Improved histology | 8.00 (3.40;18.87)
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^ | 2 | End | Mutation | 13.45 (6.14;29.45)
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^ | 2 | End | Normalization ALT | 62.18 (58.83;65.72)*
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^ | 1 | End | Relapse | 15.47 (6.53;36.64)
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^ | 1 | End | Resistance | 11.81 (8.47;16.49)
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^ | 1 | End | HBsAg loss | 5.99 (5.76;6.23)
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^ | 1 | Follow | Combined | 23.72 (22.26;25.27)
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^ | 1 | Follow | Death | 1.99 (1.92;2.07)
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^ | 1 | Follow | Decompensation | 1.08 (1.06;1.09)
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^ | 2 | Follow | HBeAg loss | 32.46 (30.71;34.31)
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^ | 1 | Follow | Flare | 14.01 (12.71;15.46)
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^ | 2 | Follow | HBeAg seroconversion | 10.67 (10.35;11.00)
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^ | 1 | Follow | HBV DNA loss | 1.16 (1.14;1.18)
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^ | 1 | Follow | Improved histology | 11.02 (10.39;11.69)
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^ | 1 | Follow | Normalization ALT | 29.96 (27.71;32.41)
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^ | 1 | Follow | Relapse | 1.19 (1.17;1.21)
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^ | 2 | Follow | HBsAg loss | 6.49 (6.31;6.67)
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^ | 2 | | Alopecia | 33.19 (16.23;67.87)
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^ | 2 | | Arthralgia | 17.60 (9.59;32.31)
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^ | 2 | | Headache | 39.63 (37.03;42.43)
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^ | 1 | | Abdominal discomfort | 44.00 (43.87;44.13)
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^ | 1 | | Abdominal pain | 16.00 (15.94;16.06)
Peginterferon alfa-2b + Lamivudine ^59,^,^78,^,^117,122^
1 | | Allergic rashes | 18.00 (17.90;18.10)
1 | | Anorexia | 14.00 (13.95;14.05)
1 | | Decreased neutrophil count | 2.00 (1.96;2.04)
1 | | Decreased phosphate level | 4.00 (3.95;4.05)
1 | | Depression | 18.00 (17.94;18.06)
1 | | Diarrhea | 9.00 (8.96;9.04)
1 | | Dizziness | 16.00 (15.90;16.10)
1 | | Fatigue | 36.00 (35.92;36.08)
1 | | Fever | 72.00 (71.88;72.12)
1 | | Flu-like syndrome | 63.00 (62.92;63.08)
1 | | Increased alkaline phosphatase level | 1.00 (0.97;1.03)
1 | | Increased ALT level | 16.00 (15.90;16.10)
1 | | Increased Creatine kinase level | 1.00 (0.97;1.03)
1 | | Insomnia | 13.00 (12.95;13.05)
1 | | Local erythematous reaction | 24.00 (23.89;24.11)
1 | | Local reaction | 25.00 (24.93;25.07)
1 | | Loss of >10% bodyweight | 16.00 (15.94;16.06)
1 | | Malaise | 44.00 (43.87;44.13)
1 | | Myalgia | 26.00 (25.88;26.12)
1 | | Myalgia | 28.00 (27.93;28.07)
1 | | Nausea | 9.00 (8.96;9.04)
1 | | Neutropenia (<1.5*109/L) | 22.00 (21.93;22.07)
1 | | Pruritus | 12.00 (11.95;12.05)
1 | | Reduced appetite | 24.00 (23.89;24.11)
1 | | Reduction in dose of Interferon due to adverse events | 24.00 (23.93;24.07)
1 | | Thrombocytopenia (<75*109/L) | 9.00 (8.96;9.04)
1 | | Upper respiratory tract symptoms | 74.00 (73.88;74.12)
1 | | Vomiting or diarrhea | 14.00 (13.91;14.09)
1 | | Weight loss (>10%) | 14.00 (13.91;14.09)
Telbivudine ^44,72^ | 2 | End | Normalization ALT | 82.35 (77.60;87.38)
Telbivudine ^44,72^
Telbivudine ^44,72^ | 2 | End | Combined | 49.71 (30.50;81.01)
Telbivudine ^44,72^
Telbivudine ^44,72^ | 2 | End | HBeAg loss | 27.44 (19.93;37.79)
Telbivudine ^44,72^
Telbivudine ^44,72^ | 2 | End | HBeAg seroconversion | 25.95 (19.72;34.14)
Telbivudine ^44,72^
Telbivudine ^44,72^ | 2 | End | HBV DNA loss | 55.26 (46.49;65.67)
Telbivudine ^44,72^
Telbivudine ^44,72^ | 2 | End | Relapse | 5.00 (4.80;5.22)
Telbivudine ^44,72^
Telbivudine ^44,72^ | 2 | End | Resistance | 1.99 (1.94;2.05)
Telbivudine ^44,72^
Telbivudine ^44,72^ | 1 | | Abdominal pain | 4.02 (3.85;4.19)
Telbivudine ^44,72^
Telbivudine ^44,72^ | 1 | | Allergic rhinitis | 1.12 (1.10;1.13)
Telbivudine ^44,72^
Telbivudine ^44,72^ | 1 | | Arthralgia | 4.02 (3.85;4.19)
Telbivudine ^44,72^
Telbivudine ^44,72^ | 1 | | At least one adverse event | 70.42 (66.40;74.68)
Telbivudine ^44,72^
Telbivudine ^44,72^ | 2 | | Back pain | 4.74 (3.28;6.87)
Telbivudine ^44,72^
Telbivudine ^44,72^ | 2 | | Cough | 5.24 (3.63;7.56)
Telbivudine ^44,72^
Telbivudine ^44,72^ | 1 | | Depression | 2.48 (2.16;2.84)
Telbivudine ^44,72^
Telbivudine ^44,72^ | 2 | | Diarrhea | 7.36 (5.82;9.30)
Telbivudine ^44,72^
Telbivudine ^44,72^ | 2 | | Dizziness | 3.37 (2.61;4.36)
Telbivudine ^44,72^
Telbivudine ^44,72^ | 1 | | Dyspepsia | 3.26 (2.54;4.18)
Telbivudine ^44,72^
1 | | Epigastric discomfort | 4.02 (3.85;4.19)
2 | | Fatigue | 8.10 (6.03;10.90)
1 | | Gastritis | 7.03 (6.65;7.43)
2 | | Headache | 8.92 (6.77;11.75)
1 | | Hepatic steatosis | 4.02 (3.85;4.19)
1 | | Hordeolum | 4.02 (3.85;4.19)
1 | | Increased Creatine phosphokinase level | 5.00 (4.87;5.14)
2 | | Influenza | 17.16 (14.26;20.64)
1 | | Malaise | 7.03 (6.65;7.43)
1 | | Mouth ulceration | 1.12 (1.10;1.13)
1 | | Myalgia | 1.99 (1.94;2.05)
2 | | Nasopharyngitis | 4.23 (3.16;5.67)
2 | | Nausea | 5.10 (4.57;5.68)
2 | | Pharyngolaryngeal pain | 5.79 (3.88;8.64)
1 | | Toothache | 4.02 (3.85;4.19)
1 | | Total adverse effect | 75.94 (69.89;82.53)
2 | | Upper abdominal pain | 7.00 (5.95;8.24)
2 | | Upper respiratory tract infection | 6.70 (4.06;11.04)
Telbivudine + Lamivudine^72^ | 1 | | Back pain | 10.00 (9.88;10.12)
Telbivudine + Lamivudine^72^
Telbivudine + Lamivudine^72^ | 1 | | Depression | 5.00 (4.91;5.09)
Telbivudine + Lamivudine^72^
Telbivudine + Lamivudine^72^ | 1 | | Diarrhea | 5.00 (4.91;5.09)
Telbivudine + Lamivudine^72^
Telbivudine + Lamivudine^72^ | 1 | | Increased Creatine phosphokinase level | 5.00 (4.91;5.09)
Telbivudine + Lamivudine^72^
Telbivudine + Lamivudine^72^ | 1 | | Upper respiratory tract infection | 10.00 (9.88;10.12)
Telbivudine + Lamivudine^72^
Telbivudine + Lamivudine^72^ | 1 | End | Normalization ALT | 78.08 (74.29;82.07)
Telbivudine + Lamivudine^72^
Telbivudine + Lamivudine^72^ | 1 | End | Combined | 35.49 (18.71;67.30)
Telbivudine + Lamivudine^72^
Telbivudine + Lamivudine^72^ | 1 | End | HBeAg loss | 16.95 (15.59;18.42)
Telbivudine + Lamivudine^72^
Telbivudine + Lamivudine^72^ | 1 | End | HBeAg seroconversion | 15.03 (14.02;16.11)
Telbivudine + Lamivudine^72^
Telbivudine + Lamivudine^72^ | 1 | End | HBV DNA loss | 48.91 (44.39;53.89)
Telbivudine + Lamivudine^72^
Telbivudine + Lamivudine^72^ | 1 | End | Relapse | 11.94 (11.14;12.80)
1 | | At least one adverse | 70.51 (65.96;75.37)
1 | | Cough | 7.05 (3.59;13.87)
1 | | Dizziness | 7.05 (3.59;13.87)
1 | | Dyspepsia | 2.45 (2.33;2.57)
1 | | Fatigue | 7.05 (3.59;13.87)
1 | | Headache | 13.71 (7.32;25.66)
1 | | Influenza | 23.76 (15.14;37.30)
1 | | Nasopharyngitis | 7.05 (3.59;13.87)
1 | | Nausea | 4.88 (1.20;19.80)
1 | | Pharyngolaryngeal pain | 5.98 (0.99;36.31)
1 | | Upper abdominal pain | 4.88 (1.20;19.80)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^ | 11 | | HBV DNA loss | 7.18 (4.44;11.61)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^ | 7 | | HBsAg loss | 1.73 (1.46;2.06)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^ | 2 | | Mutation | 2.26 (1.50;3.39)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^ | 2 | | Flare | 12.85 (6.00;27.49)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^ | 4 | | Failure | 17.60 (11.63;26.64)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^ | 8 | | HBeAg loss | 10.15 (8.61;11.97)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^ | 8 | | HBeAg seroconversion | 7.33 (6.36;8.44)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^ | 4 | | Relapse | 3.32 (1.53;7.17)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^ | 9 | | Normalization ALT | 12.32 (9.05;16.78)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^ | 6 | | Improved histology | 23.18 (18.44;29.12)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^ | 3 | | Resistance | 32.44 (11.19;94.07)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^ | 7 | | Combined | 4.82 (3.24;7.16)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^ | 2 | | Death | 7.91 (4.73;13.21)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^ | 1 | | HBsAg seroconversion | 5.00 (4.63;5.41)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^ | 1 | | Cirrhosis | 9.97 (8.87;11.22)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^ | 1 | | Flatulence | 5.99 (5.83;6.16)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^ | 6 | | Headache | 17.23 (10.96;27.08)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^ | 1 | | Respiratory infection | 29.08 (27.13;31.17)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^ | 1 | | Abdominal distention | 6.22 (3.08;12.59)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^ | 1 | | Abnormal ALT/AST | 15.96 (14.89;17.10)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^ | 1 | | ALT> 2 than at baseline | 5.31 (3.87;7.29)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^ | 1 | | Anorexia | 5.00 (4.87;5.14)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^ | 1 | | Back pain | 7.03 (6.84;7.23)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^ | 1 | | Chest symptoms | 7.03 (6.74;7.33)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^ | 3 | | Cough | 11.45 (6.74;19.44)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^ | 1 | | Creatinine mg/dL (>2.0–3.0) | 0.30 (0.29;0.31)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^ | 2 | | Depression | 3.32 (2.29;4.82)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^ | 6 | | Diarrhea | 7.11 (3.58;14.09)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^ | 4 | | Dizziness | 7.00 (5.33;9.20)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^ | 1 | | Ear, nose, and throat | 29.58 (27.49;31.82)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^ | 2 | | Fever | 1.64 (0.92;2.94)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^ | 1 | | Hair loss | 5.00 (4.87;5.14)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^ | 2 | | Leucopenia | 4.45 (3.59;5.52)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^ | 2 | | Malaise and fatigue | 22.00 (18.42;26.28)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^ | 2 | | Muscle pain | 8.64 (7.94;9.41)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^ | 2 | | Musculoskeletal pain | 4.16 (3.31;5.23)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^ | 2 | | Nasal signs and symptoms | 6.21 (5.17;7.47)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^ | 2 | | Nausea and vomiting | 2.88 (1.66;5.00)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^ | 1 | | Nausea/vomiting | 20.09 (18.74;21.53)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^ | 2 | | Pain | 9.54 (6.75;13.47)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^ | 2 | | Rash | 5.67 (2.88;11.14)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^ | 1 | | Rheumatism | 4.02 (3.85;4.19)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^ | 1 | | Throat discomfort | 8.00 (7.68;8.34)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^ | 1 | | Viral respiratory infection | 0.90 (0.88;0.91)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^ | 1 | | >1 treatment-related event | 12.00 (11.94;12.06)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^ | 1 | | »1 adverse event | 76.71 (71.57;82.21)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^ | 1 | | Abdominal discomfort | 20.31 (17.65;23.37)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^ | 1 | | Abdominal pain and discomfort | 4.00 (3.96;4.04)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^ | 1 | | Abnormal enzymes (amylase/CPK) | 7.03 (6.74;7.33)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^ | 1 | | Abnormal liver-function | 8.00 (7.68;8.34)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^ | 1 | | ALT »2 times above base-line levels and bilirubin »2 times above baseline levels | 0.84 (0.59;1.19)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^ | 1 | | Collapse after dizziness | 0.00 (0.85;0.90)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^ | 1 | | Constipation | 4.00 (3.96;4.04)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^ | 1 | | Creatinine mg/dL (>3.0–6.0) | 0.30 (0.29;0.31)
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^
Placebo or no treatment ^40,^,^42,^,^47,^,^48,^,^50,^,^53,^,^83,^,^86,^,^87,^,^89,^,^93,^,^94,^,^96,^,^99,^,^100,103^–^105,^,^108,^,^110,112^ | 1 | | Creatinine mg/dL (>6.0)- | 0.30 (0.29;0.31)
1 | | Creatinine mg/dL (1.5–2.0) | 0.30 (0.29;0.31)
1 | | Decreased WBCs | 0.90 (0.88;0.91)
1 | | Developing of IFN neutralizing antibodies | 0.00 (1.74;1.83)
1 | | Discontinuation due to adverse events | 1.00 (0.99;1.01)
1 | | Discontinuation due to depression | 0.00 (1.74;1.83)
3 | | Discontinuation due to adverse effects | 1.65 (0.83;3.29)
1 | | Discontinuation due to psychosis | 0.00 (1.74;1.83)
1 | | Dose reduced due to an adverse event or abnormal lab result | 1.00 (0.99;1.01)
1 | | Dose reduction due to depression, fatigue, hair loss, and headache | 0.00 (0.85;0.90)
3 | | Fatigue | 4.61 (2.91;7.30)
1 | | Feeding problems | 4.02 (3.85;4.19)
1 | | Gastrointestinal events | 6.00 (5.96;6.04)
1 | | Glycosuria(+1) | 3.00 (2.97;3.03)
1 | | Glycosuria(+2) | 2.00 (1.98;2.02)
1 | | Glycosuria(+3) | 3.00 (2.97;3.03)
1 | | Glycosuria(+4) | 0.30 (0.29;0.31)
1 | | Grade III or IV lab abnormalities in alanine aminotransferase | 13.00 (12.92;13.08)
1 | | Grade III or IV laboratory abnormalities in Albumin | 3.00 (2.96;3.04)
1 | | Grade III or IV laboratory abnormalities in Amylase | 1.00 (0.98;1.02)
1 | | Grade III or IV laboratory abnormalities in Creatine kinase | 4.00 (3.96;4.04)
1 | | Grade III or IV laboratory abnormalities in Lipase | 7.00 (6.94;7.06)
1 | | Grade III or IV laboratory abnormalities in Platelets | 3.00 (2.96;3.04)
1 | | Grade IV abnormality in ALT | 0.84 (0.59;1.19)
1 | | Hair loss/alopecia | 4.02 (3.85;4.19)
1 | | Hematuria Obstructive or Rx required | 0.00 (0.29;0.31)
1 | | Hematuria<10 RBCs | 7.00 (6.96;7.04)
1 | | Hematuria>100 RBCs | 13.00 (12.95;13.05)
1 | | Hematuria10–100 RBCs | 10.00 (9.96;10.04)
1 | | Hypophosphatemia mg/dL (<1.0) | 0.30 (0.29;0.31)
1 | | Hypophosphatemia mg/dL (1.0–1.5) | 0.30 (0.29;0.31)
1 | | Hypophosphatemia mg/dL (1.5–<2.0) | 1.00 (0.99;1.01)
1 | | Hypophosphatemia mg/dL (2.0–2.2) | 1.00 (0.99;1.01)
1 | | Incidence of elevation of serum ALT to >5 times the ULN | 55.15 (52.17;58.29)
1 | | Infections | 0.00 (2.22;2.33)
1 | | Jaundice | 0.00 (2.22;2.33)
1 | | Liver symptoms | 4.00 (3.96;4.04)
1 | | Malaise/fatigue | 32.14 (29.57;34.92)
1 | | Marrow suppression | 0.00 (2.22;2.33)
1 | | Muscular or skeletal pain | 4.00 (3.96;4.04)
1 | | Nasopharyngitis | 1.99 (1.97;2.02)
2 | | Nausea | 7.64 (2.33;25.09)
1 | | Paresthesias | 7.00 (6.94;7.06)
1 | | Proteinuria mg/dL(Nephrotic syndrome) | 0.00 (0.29;0.31)
1 | | Proteinuria mg/dL(<100) | 10.00 (9.96;10.04)
1 | | Proteinuria mg/dL(>1000) | 0.30 (0.29;0.31)
1 | | Proteinuria mg/dL100–1000) | 7.00 (6.96;7.04)
1 | | Pruritis | 4.00 (3.96;4.04)
1 | | Sleep disorder | 4.00 (3.96;4.04)
1 | | Sleep disturbance | 4.00 (3.96;4.04)
1 | | Temperature regulation disturbance | 6.92 (5.88;8.16)
1 | | Throat and tonsil disorder | 16.95 (15.83;18.14)
1 | | Upper respiratory tract infection | 8.00 (7.79;8.23)
1 | | Upper respiratory viral infection | 4.00 (3.96;4.04)
1 | | Viral respiratory infection | 27.52 (18.01;42.07)

* estimates from fixed effects model when the best fit; all estimations were calculated in log odds scale,

† exponentiated estimates were pooled

Table E12 Summary of study IDs meeting eligibility for question 4

Surrogates | Outcomes
| Decompensation (Liver Failure) | Cirrhosis | HCC | Liver-Related Mortality | All-Cause Mortality
ALT normalization during treatment | Di Marco^127^* | Di Marco^127^* | Di Marco^127^* | | Di Marco^127^*
HBV DNA detectable end of treatment | Brunetto^128^* and Hui^129^* | Brunetto^128^* and Hui^129^* | Brunetto^128^* and Hui^129^*
Worsening histology | Hui^129^* | Hui^129^* | Hui^129^*
Change in HBeAg status | Chan^117^
HBsAg seroconversion
Drug Resistance

* Three studies reported on combined clinical outcome of Decompensation+ Cirrhosis+ HCC

Table E13 Evidence table of the studies that examined the association between changes in intermediate outcomes to predict treatment effectiveness (n=4)

Surrogates | Outcomes
| Decompensation (Liver failure) | Cirrhosis | HCC | Liver-related mortality | All cause mortality
Chronic hepatitis B Interferon alpha vs. untreated^127^
ALT normalization during treatment* | RR 0.24 (.10–.59) | | | | RR 0.24 (.08–.69)
HBV DNA detectable end of treatment
Worsening histology
Change in HBeAg status
HBsAg seroconversion
Drug Resistance
HBeAg positive chronic hepatitis B Interferon alpha 2a vs. untreated^128^
ALT normalization during treatment
HBV DNA detectable during/ end of treatment^§^ | OR 1.58 (1.12– 2.25)
Worsening histology
Change in HBeAg status
HBsAg seroconversion
Drug resistance
HBeAg positive chronic hepatitis B All treated with peginterferon alpha 2a or 2b^129^ Lamivudine plus peginterferon alpha 2b vs. lamivudine^117^
ALT normalization during treatment
HBV DNA detectable at end of treatment^#^ | OR 3.08 (0.44– 22.7)
Worsening histology^&^ | RR 5.56 (1.12– 27.62)
Loss of HBeAg end of treatment | ORˆ 0.6 (0.03–9.01) O% 0.81 (0.09– 7.64)
HBsAg seroconversion
Drug Resistance

* Adjusted for age, cirrhosis at baseline and interferon alpha treatment. Combined endpoint of decompensation includes ascites, jaundice, encephalopathy, portal hypertensive bleeding and HCC & 2 point increase in modified HAI on serial liver biopsies. Combined clinical outcome of ‘Liver complications’ reported including decompensated cirrhosis and HCC. Multivariate analysis, adjusted for ‘other risk factors.’

§ HBV DNA pattern1 (always or frequently > 10 pg/ml). OR from multivariate analysis adjusted for age, HBeAg at baseline and interferon alpha treatment for composite end point of ‘disease progression’ defined as progression to cirrhosis, decompensation or HCC.

4 HBV DNA ≥10 copies/ml at 24 weeks after end of treatment. Unadjusted OR; calculated from frequencies reported in table.

ˆ Unadjusted OR calculated from reported frequencies for cohort of patients treated with lamivudine plus peginterferon alpha-2b

% Unadjusted OR calculated from reported frequencies for cohort of patients treated with lamivudine alone

Table E14 Other baseline factors as predictors of outcomes, and other outcomes (n=3)

Baseline Factors | Outcomes
| Decompensation, Cirrhosis, HCC (Liver Failure) | Annual Rate of Fibrosis Progression | Liver-Related Mortality | All Cause Mortality
HBeAg-negative chronic hepatitis B Lamivudine vs. interferon alpha vs. placebo^130^ Interferon alpha vs. placebo^131^
Cirrhosis at baseline | | | Significant predictor, estimate not reported | Significant predictor, estimate not reported
Fibrosis score at baseline
Milder fibrosis at baseline (Ishak stage <4) | | OR 1.05 (1.0–1.11)
Worsening necroinflammatory grade (≥2 point increase) | | OR 1.05 (1.03–1.08)
HBeAg-positive chronic hepatitis B — all treated with Interferon alpha 2b^132^
Staging score at baseline(0–6) ^§^ | HR 1.71 (1.17–2.50)

§ From multivariate analysis controlling for age and treatment failure. Composite end point of liver-related complications

Table E15 Ongoing interventional randomized studies in patients with chronic hepatitis B (underlined outcomes assessment in patient subpopulations relevant to question 3)

Sponsor | ID | Tested Drug | Design | Outcomes
National Institute of Diabetes and Digestive and Kidney Diseases (NIDDK); National Institutes of Health Clinical Center (CC) | NCT00023309 | Adefovir Dipivoxil | Phase 2, Randomized, Open Label, Parallel Assignment, Safety/Efficacy Study | Maintained combined response (virological, biochemical and histological response). Loss of HBeAg, individual responses (virological, biochemical and histological), antiviral resistance and improvement in symptom scores
National Institute of Diabetes and Digestive and Kidney Diseases (NIDDK); National Institutes of Health Clinical Center (CC) | NCT00524173 | Tenofovir Disoproxil Fumarate Alone vs. Its Combination With Emtricitabine | Phase 2, Randomized, Open Label, Active Control, Parallel Assignment, Safety/Efficacy Study | Maintained suppression of HBV DNA below 102 copies/ml (<95 IU/ml, undetectable by current PCR-based assays, Roche Amplicor assay). Normalization of ALT levels and histological improvements which are expected to occur in all patients with full suppression of HBV DNA and in a proportion of those with partial suppression; loss of HBeAg and loss of HBsAg
Foundation for Liver Research | EudraCT: 2004-004736-30 | Peginterferon Alfa-2a and Ribavirin Combination (HBeAg-Negative Chronic HBV Infection (PARC Study) | Phase 3, Randomized, Double Blind (Subject, Investigator), Placebo Control, Factorial Assignment, Efficacy Study | The combined presence of HBV DNA level <10E4 copies/ml and ALT normalization at the end of followup ALT normalization; HBV DNA negativity (undetectable by Taqman PCR) HBsAg loss; Improvement liver histology; combined virological, biochemical and histological response
Achillion Pharmaceuticals | NCT00040144 | ACH126, 433 (b-L-Fd4C) | Phase 2, Randomized, Double-Blind, Dose Comparison, Parallel Assignment, Safety/Efficacy Study | Not reported
Bristol-Myers Squibb Administration | NCT00065507 | Adefovir Entecavir | Phase 3, Randomized, Open Label, Active Control, Parallel Assignment, Safety/Efficacy Study | Mean serum HBV DNA PCR adjusted for baseline levels Discontinuation or dose reduction of study drug due to clinical AE or lab abnormality. Confirmed nephrotoxicity (increase in serum creatinine compared w/ baseline)
Novartis | NCT00076336 | Lamivudine | Phase 3, Randomized, Double Blind (Subject, Caregiver, Investigator, Outcomes Assessor), Dose Comparison, Parallel Assignment, Safety/Efficacy Study | Composite endpoint termed Clinical Response, defined as three efficacy criteria: Serum HBV DNA < 4 log10 copies/mL, Normal ALT level, Improvement or stabilization in CTP score
Novartis | NCT00076336 | Telbivudine | Phase 3, Randomized, Double Blind (Subject, Caregiver, Investigator, Outcomes Assessor), Dose Comparison, Parallel Assignment, Safety/Efficacy Study | Time to Clinical Response; Duration of Clinical Response; Improvement, Stabilization, and Worsening in CTP score; Improvement, Stabilization, and Worsening in a modified (3-component) CTP score
National Institute of Allergy and Infectious Diseases (NIAID); National Institute of Child Health and Human Development (NICHD) | NCT00111943 | Tenofovir gel | Phase 2, Prevention, Randomized, Double-Blind, Placebo Control, Parallel Assignment, Safety Study | Macroscopic evidence of damage to the cervical, vulvar, or vaginal epithelium, including ulceration and other lesions, severe erythema, or severe edema, related or not related to the study gel or applicator Adherence to the study gel regimen, acceptability of the study gel
Gilead | NCT00116805 | Adefovir dipivoxil Tenofovir disoproxil fumarate | Phase III, Randomized, Double Blind (Subject, Caregiver, Investigator, Outcomes Assessor), Active Control, Parallel Assignment, Safety/Efficacy Study | HBV DNA <400 copies/mL and histological improvement (at least a 2 point reduction in the Knodell necroinflammatory score without worsening in fibrosis) HBV DNA <400 copies/mL Histological improvement ALT normalization HBeAg and HBsAg loss/seroconversion Development of resistance mutations safety and tolerability
Gilead Sciences | NCT00117676 | Adefovir dipivoxil tenofovir disoproxil fumarate | Phase III, Randomized, Double Blind (Subject, Caregiver, Investigator, Outcomes Assessor), Parallel Assignment, Safety/Efficacy Study | HBV DNA <400 copies/mL and Histological Improvement (2 point reduction in Knodell Necroinflammatory score without worsening in Knodell fibrosis score) Histological Improvement Development of resistance mutations Safety and Tolerability ALT normalization
Idenix Pharmaceuticals; Novartis | NCT00128544 | Telbivudine Valtorcitabine | Phase 2, Randomized, Double-Blind, Active Control, Parallel Assignment, Safety/Efficacy Study | Not reported
University Hospital, Bonn; Hoffmann-La Roche | NCT00221286 | Pegylated interferon alfa 2a pegylated interferon alfa 2a + tenofovir + emtricitabine tenofovir + emtricitabine | Phase 3, Randomized, Open Label, Active Control, Factorial Assignment, Safety/Efficacy Study | HBeAg seroconversion Study discontinuation due to adverse events Loss of HBe-Ag; HBV-DNA < 5×10^3^ copies/ml, (COBAS TaqMan HBV Test); decrease of HBV-DNA >2×log10 compared to baseline; normalization of ALT; Viral kinetics of HBV-DNA; Paired liver biopsy comparison according to METAVIR-activity and fibrosis score. HIV-RNA <50 copies/ml and CD4-cell increase Safety: number of adverse events, according to type and severity.
MTmedical Institute of Health The University of Texas Health Science Center at San Antonio BioMonde Preparations Limited | NCT00225537 | 4-Methylumbelliferone (Heparvit®) | Phase 2, Randomized, Double-Blind, Placebo Control, Single Group Assignment, Safety/Efficacy Study | Reduction of virus in blood to undetectable levels; Normalization of serum ALT and AST. Reduced viral loads; Improvement of serum ALT and AST; Improvement in general health status; Improvement in serum marker of hepatic fibrosis; Loss of HBeAg/seroconversion to HBeAb (for HBV patients).
Chinese University of Hong Kong; GlaxoSmithKline | NCT00226447 | Lamivudine Pegylated Interferon | Phase 2, Randomized, Open Label, Active Control, Parallel Assignment, Efficacy Study | HBV DNA reduction Normalization of ALT and negative HBV DNA at EOT, negative HBV DNA at EOT; Safety of treatment
PowderMed | NCT00277576 | HBV DNA Vaccine ppdpSC18 | Phase 1, Randomized, Double-Blind, Placebo Control, Single Group Assignment, Safety Study | Adverse events at all visits, vaccine site evaluations, laboratory parameters pre and post vaccination
Seoul National University Hospital; Hoffmann-La Roche | NCT00291616 | Pegylated Interferon-alpha 2a Thymosin alpha 1 | Phase 4, Randomized, Open Label, Historical Control, Parallel Assignment, Safety/Efficacy Study | HBeAg seroconversion, HBV DNA titer <20,000 IU/mL Normalization of serum ALT, loss of HBeAg and HBsAg, production of anti-HBs
Gilead Sciences | NCT00298363 | Emtricitabine Entecavir tenofovir disoproxil fumarate | Phase 2, Randomized, Double Blind (Subject, Investigator, Outcomes Assessor), Active Control, Parallel Assignment, Safety/Efficacy Study | Safety (adverse events and laboratory tests, discontinuations due to adverse events)
Thomas Jefferson University | NCT00307242 | Adefovir Dipivoxil | Phase 4, Randomized, Open Label, Active Control, Parallel Assignment, Safety Study | ALT elevations (>10 × ULN); serum HBV DNA levels over time; serum ALT levels; YMDD variants; safety
Gilead Sciences | NCT00307489 | Emtricitabine Tenofovir DF | Phase 2, Randomized, Double Blind (Subject, Investigator, Outcomes Assessor), Active Control, Single Group Assignment, Safety/Efficacy Study | HBV DNA <169 copies/mL
Bukwang Pharmaceutical; Hong Kong: Department of Health | NCT00362635 | Clevudine | Phase 3, Randomized, Double-Blind, Active Control, Parallel Assignment, Safety/Efficacy Study | HBV DNA negativity (i.e., <300 copies/ml) by PCR Safety: Laboratory tests, Adverse Events, Physical examination Viral kinetics of HBV DNA suppression
Bristol-Myers Squibb; Korea: Food and Drug Administration | NCT00393484 | Entecavir + Lamivudine Placebo | Phase 4, Randomized, Double Blind (Subject, Investigator), Active Control, Parallel Assignment, Efficacy Study | Undetectable HBV DNA, <300 copies/mL, by Roche COBAS Amplicor PCR assay Mean log10 reduction from baseline in HBV DNA; normalization of serum ALT (≤1 × ULN); HBV DNA < 103, <104 or <105 copies/mL
Novartis | NCT00409019 | Adefovir Telbivudine Tenofovir | Phase IV, Randomized, Double-Blind, Placebo Control, Parallel Assignment, Safety/Efficacy Study | Not reported
Bristol-Myers Squibb | NCT00410072 | Entecavir Entecavir + Tenofovir | Phase 3, Randomized, Open Label, Active Control, Parallel Assignment, Safety/Efficacy Study | HBV DNA <50 IU/mL (approximately 300 copies/mL) HBV DNA <50 IU/mL (300 copies/mL); Mean Log 10 reduction from baseline in HBV DNA by PCR; ALT Normalization (≤1 × upper limit of normal); HBeAg loss; HBe seroconversion; HBs seroconversion Frequency of adverse events, serious adverse events, and discontinuations from study drug due to adverse events or laboratory abnormalities
Bristol-Myers Squibb | NCT00410202 | Entecavir vs. Adefovir Plus Lamivudine vs. Combination Entecavir Plus Adefovir in Lamivudine-Resistant Chronic Hepatitis B Subjects: The DEFINE Study | Phase 3, Randomized, Open Label, Active Control, Parallel Assignment, Safety/Efficacy Study | HBV DNA <50 IU/mL (approximately 300 copies/mL) Mean Log10 reduction from baseline in HBV DNA; ALT normalization (≤1 × upper limit of normal); HBeAg loss; HBe seroconversion; HBs seroconversion; virologic rebound due to genotypic resistance Frequency of adverse events, serious adverse events, and discontinuations from study drug due to adverse events or laboratory abnormalities
Novartis; Idenix Pharmaceuticals | NCT00412529 | Entecavir Telbivudine | Phase 3, Randomized, Open Label, Active Control, Parallel Assignment, Safety/Efficacy Study | Change in mean hepatitis B virus (HBV) DNA level from baseline; early viral kinetics through estimation of various parameters; change in ALT levels; the area under the curve (AUC) of HBV DNA change from baseline to week 12; polymerase chain reaction (PCR) negative; Safety assessed by adverse events and laboratory values
Hoffmann-La Roche | NCT00435825 | Peginterferon alfa 2a | Phase 4, Randomized, Double Blind (Subject, Investigator), Active Control, Parallel Assignment, Safety/Efficacy Study | HBeAg seroconversion Loss of HBeAg, HBsAg seroconversion, loss of HBsAg, ALT, HBV-DNA AEs, laboratory parameters
Hoffmann-La Roche; Bulgaria: Bulgarian Drug Agency | NCT00442572 | Peginterferon alfa 2a | Phase 2, Randomized, Open Label, Active Control, Parallel Assignment, Safety/Efficacy Study | Serum HBV DNA <100,000 copies/mL Loss of HBsAg and seroconversion Changes in liver fibrosis, AEs, lab parameters
Gilead Sciences; United States: Food and Drug Administration | NCT00507507 | Tenofovir disoproxil fumarate | Phase 2, Randomized, Double Blind (Subject, Caregiver, Investigator, Outcomes Assessor), Active Control, Parallel Assignment, Safety/Efficacy Study | Suppression of HBV DNA <169 copies/mL
Gilead Sciences | NCT00507689 | Emtricitabine/tenofovir disoproxil fumarate Emtricitabine/tenofovir disoproxil fumarate + Hepatitis B Immunoglobulin | Phase 2, Prevention, Randomized, Open Label, Active Control, Parallel Assignment, Safety/Efficacy Study | Recurrence of Chronic Hepatitis B virus post liver transplant
Genexine Co., Ltd.; Korea: Food and Drug Administration | NCT00513968 | Adefovir | Phase 1, Randomized, Open Label, Active Control, Parallel Assignment, Safety/Efficacy Study | Adverse events and clinical laboratory abnormalities; HBeAg/HBsAg seroconversion rate, HBV Ag specific T cell immunity
Korea University; GlaxoSmithKline | NCT00531167 | Entecavir Lamivudine + Adefovir | Phase 4, Randomized, Open Label, Active Control, Parallel Assignment, Efficacy Study | PCR negativity (<60 IU/ml) of HBV DNA 1. PCR negativity (<60 IU/ml) of HBV DNA at year 1 (interim analysis) 2. Degrees of HBV DNA reduction 3. ALT normalization 4. HBeAg seroconversion 5. Development of resistant mutation 6. Virologic breakthrough 7. Biochemical breakthrough
Schering-Plough; China: State Food and Drug Administration | NCT00536263 | Pegylated interferon alpha-2b | Phase 3, Randomized, Open Label, Active Control, Crossover Assignment | HBeAg Loss; HBe seroconversion; HBV-DNA decrease; ALT normalization Combined Response (defined as HBV DNA (PCR) <20,000 IUs/ml and HBe seroconversion and ALT normalization) HBsAg Loss; HBs seroconversion
French National Agency for Research on AIDS and Viral Hepatitis | NCT00536627 | Naked DNA vaccine pCMVS2.S | Phase 1/Phase 2, Randomized, Open Label, Parallel Assignment, Safety/Efficacy Study | Virologic failure defined by 1) reactivation after analogs' treatment interruption, 2) virologic breakthrough during treatment with analogs, 3) the impossibility for the patients to interrupt treatment at week 48
National Taiwan University Hospital; Bristol-Myers Squibb | NCT00597259 | Entecavir Pegasys plus Entecavir | Phase 4, Randomized, Open Label, Active Control, Parallel Assignment, Efficacy Study | HBeAg seroconversion Serum ALT normalization, HBeAg loss, serum HBV DNA disappearance, HBsAg disappearance, histological change, Entecavir resistance
Bristol-Myers Squibb | NCT00605384 | Adefovir +Lamivudine Entecavir + Tenofovir | Phase 3, Randomized, Open Label, Active Control, Parallel Assignment, Safety/Efficacy Study | HBV DNA level <50 IU/mL
Hoffmann-La Roche; China: State Food and Drug Administration | NCT00614471 | Entecavir peginterferon alfa-2a | Phase 4, Randomized, Open Label, Active Control, Parallel Assignment, Safety/Efficacy Study | Log change in quantitative HBeAg from baseline HBeAg seroconversion, HBV-DNA <1000 copies/mL, loss of HBeAg, HBV DNA reduction, ALT normalization, loss of HBsAg seroconversion, reduction of HBsAg 24 weeks after end of treatment; AEs, laboratory parameters
Pusan National University Hospital; Yonsei University | NCT00625339 | Entecavir Lamivudine | Phase 4, Randomized, Open Label, Active Control, Parallel Assignment, Safety/Efficacy Study | HBV DNA <60 IU/mL (Undetectable serum HBV DNA by PCR method); drug resistant mutations; ALT normalization, HBeAg loss, HBe seroconversion, HBsAg loss and HBs seroconversion Cumulative discontinuation rates due to lamivudine or entecavir resistance mutations and clinical breakthrough, Safety assessment
Yonsei University; Pusan National University Hospital; Yonsei University | NCT00625560 | Entecavir Lamivudine | Phase 4, Randomized, Open Label, Active Control, Parallel Assignment, Safety/Efficacy Study | HBV DNA < 60 IU/mL Drug resistant mutations; change from baseline in mean HBV DNA; ALT normalization, HBeAg loss, HBe seroconversion, HBsAg loss and HBs seroconversion Cumulative discontinuation rates due to lamivudine or entecavir resistance mutations and clinical breakthrough Safety assessment
Yonsei University; Pusan National University Hospital | NCT00637663 | Entecavir Lamivudine | Phase 4, Randomized, Open Label, Active Control, Parallel Assignment, Safety/Efficacy Study | HBV DNA <60 IU/mL (Undetectable serum HBV DNA by PCR method); ALT normalization, HBeAg loss, HBe seroconversion, HBsAg loss and HBs seroconversion Cumulative discontinuation rates due to lamivudine or Entecavir resistance mutations and clinical breakthrough, Safety assessment
Bukwang Pharmaceutical; South Korea: Korea Food and Drug Administration (KFDA) | NCT00641082 | Adefovir Clevudine | Phase 4, Randomized, Double-Blind, Parallel Assignment, Safety/Efficacy Study | HBV DNA below 300copies/mL The change of HBV DNA from the baseline; HBV DNA below LOD of RT-PCR; ALT normalization rate; viral breakthrough
Hoffmann-La Roche; Turkey: Ministry of Health | NCT00661076 | Adefovir dipivoxil Peginterferon alfa-2a | Phase 3, Randomized, Open Label, Active Control, Parallel Assignment, Safety/Efficacy Study | Normalization of ALT, and HBV-DNA <400 copies/mL HBsAg quantitative loss and anti-HBs seroconversion; AEs, lab parameters, vital signs
University of Ulm; Novartis | NCT00710216 | Lamivudine Telbivudine | Phase 4, Randomized, Open Label, Active Control, Parallel Assignment, Pharmacokinetics/Dynamics Study | Decrease in viral load after 2 weeks of therapy measured in serum HBV-DNA concentration (Copies/ml or IU/ml) Influence of HBeAg status to the decrease in viral load Influence of HBV genotype to the decrease in viral load Change in ALT and AST levels from baseline to week 12 Development of viral resistance and treatment failure during the study and subsequent course of observation Safety assessed by adverse events and laboratory values
Maimonides Medical Center | NCT00715715 | Prednisone Priming | Randomized, Single Blind (Subject), Placebo Control, Parallel Assignment, Safety/Efficacy Study | Reduction in HBV DNA, HBeAg seroconversion, normalization of ALT; histological improvement
Bristol-Myers Squibb; China: State Food and Drug Administration | NCT00718887 | Adefovir, then Entecavir Entecavir | Phase 4, Randomized, Open Label, Active Control, Crossover Assignment, Safety/Efficacy Study | HBV DNA <50 IU/mL Mean reduction of HBV DNA; ALT normalization; HBeAg loss, seroconversion, HBsAg loss and seroconversion Safety Resistance
Gilead Sciences | NCT00734162 | Tenofovir disoproxil fumarate | Phase 2/Phase 3, Randomized, Double Blind (Subject, Investigator), Placebo Control, Parallel Assignment, Safety/Efficacy Study | Composite endpoint of HBV DNA <400 copies/mL and ALT normal Adverse events and clinical laboratory tests
Gilead Sciences | NCT00737568 | Emtricitabine/tenofovir DF Tenofovir DF | Phase 4, Randomized, Double Blind (Subject, Investigator), Active Control, Parallel Assignment, Safety/Efficacy Study | Antiviral efficacy against HBV; safety and tolerability

Table E16 Completed unpublished RCTs in patients with chronic hepatitis B

Sponsor | ID | Tested Drug | Phase | Design | Outcomes
Mayo Clinic; Idenix Pharmaceuticals | NCT00275652 | LdT (Telbivudine) and lamivudine | Phase 3 | Randomized, Double-Blind, Active Control, Parallel Assignment, Safety/Efficacy Study | A composite endpoint called “clinical response” which is defined as HBV DNA <10 4 copies/ml and normal ALT and improvement, or stabilization in CTP score. Improvement, stabilization, and worsening in CTP score; normal ALT; improvements in serum albumin levels, in patients with hypoalbuminemia pre-treatment
GlaxoSmithKline | NCT00316719 | Adefovir dipivoxil | Phase 3 | Randomized, Double-Blind, Active Control, Parallel Assignment, Safety/Efficacy Study | Change in serum HBV-DNA level from baseline to week 52 HBV-DNA level; ALT level and proportion of patients achieving ALT normalization; Emergence rate of resistant virus
Idenix Pharmaceuticals; Novartis | NCT00124241 | Telbivudine lamivudine | Phase 2 | Randomized, Double-Blind, Active Control, Parallel Assignment, Safety/Efficacy Study | Not reported
Bristol-Myers Squibb; Bristol-Myers Squibb | NCT00096785 | Entecavir adefovir | Phase 3 | Randomized, Open Label, Active Control, Parallel Assignment, Safety/Efficacy Study | Antiviral efficacy, as measured by the mean reduction in serum HBV DNA levels by PCR(log10 copies/mL) Exploratory viral kinetics: HBV DNA by PCR<LOQ and normalization of ALT (<1×ULM). Relapse during 24-week post-dosing phase for those who achieve Response. Safety: Number and percentage of subjects with AEs, lab abnormalities and discontinuations due to AEs
Valeant Pharmaceuticals North America; Valeant Pharmaceuticals North America | NCT00230503 | Pradefovir mesylate adefovir dipivoxyl | Phase 2 | Randomized, Open Label, Active Control, Parallel Assignment, Safety Study | Safety: Clinical examinations of laboratory tests Change in viral load over time Undetectable viral load
University of Washington; Gilead Sciences; GlaxoSmithKline | NCT00230477 | Hepsera Hepsera and lamivudine | Phase 4 | Randomized, Open Label, Dose Comparison, Parallel Assignment, Efficacy Study | Decrease in the viral DNA HBeAg conversion
National Taiwan University Hospital; Schering-Plough | NCT00275938 | Interferon alpha 2b plus ribavirin interferon alpha 2b plus placebo | Phase 2/Phase 3 | Randomized, Double-Blind, Placebo Control, Parallel Assignment, Safety/Efficacy Study | Undetected serum HBV DNA level (i.e., less than 2.5 pg/ml) at the end of the 24-week followup period HBV DNA level at the end of treatment Clearance of HBeAg and rate of ALT normalization both at the end of the 32-week treatment period and at the end of the 24-week followup
GlaxoSmithKline; Schering-Plough | NCT00140725 | Lamivudine plus Polyethylene glyco-interferon alfa 2b Lamivudine | Phase 3 | Randomized, Open Label, Uncontrolled, Parallel Assignment, Safety/Efficacy Study | HBeAg seroconversion to anti-HBe Normalization of ALT Undetectable HBV DNA Histologic improvement Tyrosine, methionine, aspartate, aspartate (YMDD) mutants among the viremic relapsers at the end of therapy and safety of treatment
Achillion Pharmaceuticals | NCT00034359 | ACH-126, 443 (beta-L-Fd4C) | Phase 2 | Randomized, Double-Blind, Dose Comparison, Parallel Assignment, Safety/Efficacy Study | Not reported
Idenix Pharmaceuticals; Novartis | NCT00132652 | Lamivudine Telbivudine | Phase 3 | Randomized, Double-Blind, Active Control, Parallel Assignment, Safety/Efficacy Study | Not reported
Chinese University of Hong Kong; GlaxoSmithKline | NCT00338780 | Lamivudine/Placebo 100mg daily | Phase 4 | Randomized, Double-Blind, Placebo Control, Parallel Assignment, Safety/Efficacy Study | Complete response (ALT<17×ULN and disappearance of HBV DNA, lower limit of detection) Histological improvement at month 24 Progression of fibrosis Progression of fibrosis to cirrhosis HBsAg seroconversion Safety of treatment

## References for Appendix E

(Note that there is a separate set of references at the end of the report and reference numbers are different than those in Appendix E)

1 Livingston SE, Simonetti JP, McMahon BJ, et al. Hepatitis B virus genotypes in Alaska Native people with hepatocellular carcinoma: preponderance of genotype F.[see comment]. Journal of Infectious Diseases. Jan 1. 2007;195(1):5-11. [pmid: 17152003].
2 McMahon BJ, Holck P, Bulkow L, et al. Serologic and clinical outcomes of 1536 Alaska Natives chronically infected with hepatitis B virus.[see comment]. Annals of Internal Medicine. Nov 6. 2001;135(9):759-68. [pmid: 11694101].
3 McMahon BJ, Bulkow L, Harpster A, et al. Screening for hepatocellular carcinoma in Alaska natives infected with chronic hepatitis B: a 16-year population-based study. Hepatology. Oct. 2000;32(4 Pt 1):842-6. [pmid: 11003632].
4 McMahon BJ, Alberts SR, Wainwright RB, et al. Hepatitis B-related sequelae. Prospective study in 1400 hepatitis B surface antigen-positive Alaska native carriers. Archives of Internal Medicine. May. 1990;150(5):1051-4. [pmid: 2158773].
5 Tong MJ, Blatt LM, Kao JH, et al. Basal core promoter T1762/A1764 and precore A1896 gene mutations in hepatitis B surface antigen-positive hepatocellular carcinoma: a comparison with chronic carriers. Liver Int. Dec. 2007;27(10):1356-63. [pmid: 17900245].
6 Tong MJ, Blatt LM, Kao JH, et al. Precore/basal core promoter mutants and hepatitis B viral DNA levels as predictors for liver deaths and hepatocellular carcinoma. World J Gastroenterol. Nov 7. 2006;12(41):6620-6. [pmid: 17075974].
7 Tong MJ, Blatt LM, Tyson KB, et al. Death from liver disease and development of hepatocellular carcinoma in patients with chronic Hepatitis B virus infection: a prospective study. Gastroenterology & Hepatology. Jan. 2006;2(1):41-7.
8 Tong MJ, Blatt LM, Kao VW, et al. Surveillance for hepatocellular carcinoma in patients with chronic viral hepatitis in the United States of America. Journal of Gastroenterology & Hepatology. May. 2001;16(5):553-9. [pmid: 11350553].
9 Schiodt FV, Davern TJ, Shakil AO, et al. Viral hepatitis-related acute liver failure. Am J Gastroenterol. Feb. 2003;98(2):448-53. [pmid: 12591067].
10 Thio CL, Seaberg EC, Skolasky R Jr, et al. HIV-1, hepatitis B virus, and risk of liver-related mortality in the Multicenter Cohort Study (MACS). Lancet. Dec 14. 2002;360(9349):1921-6. [pmid: 12493258].
11 Abiad H, Ramani R, Currie JB, et al. The natural history of hepatitis D virus infection in Illinois state facilities for the developmentally disabled. American Journal of Gastroenterology. Feb. 2001;96(2):534-40. [pmid: 11232702].
12 Nomura A, Stemmermann GN, Chyou PH, et al. Hepatitis B and C virus serologies among Japanese Americans with hepatocellular carcinoma. Journal of Infectious Diseases. Jun. 1996;173(6):1474-6. [pmid: 8648223].
13 Norman JE, Beebe GW, Hoofnagle JH, et al. Mortality follow-up of the 1942 epidemic of hepatitis B in the U.S. Army. Hepatology. Oct. 1993;18(4):790-7. [pmid: 8406352].
14 Weissberg JI, Andres LL, Smith CI, et al. Survival in chronic hepatitis B. An analysis of 379 patients. Ann Intern Med. Nov. 1984;101(5):613-6. [pmid: 6486592].
15 Sherman M, Peltekian KM, Lee C. Screening for hepatocellular carcinoma in chronic carriers of hepatitis B virus: incidence and prevalence of hepatocellular carcinoma in a North American urban population. Hepatology. Aug. 1995;22(2):432-8. [pmid: 7543434].
16 Amin J, Dore GJ, O'Connell DL, et al. Cancer incidence in people with hepatitis B or C infection: a large community-based linkage study. Journal of Hepatology. Aug. 2006;45(2):197-203. [pmid: 16684579].
17 Konopnicki D, Mocroft A, de Wit S, et al. Hepatitis B and HIV: prevalence, AIDS progression, response to highly active antiretroviral therapy and increased mortality in the EuroSIDA cohort.[see comment]. AIDS. Mar 24. 2005;19(6):593-601. [pmid: 15802978].
18 Ribes J, Cleries R, Rubio A, et al. Cofactors associated with liver disease mortality in an HBsAg-positive Mediterranean cohort: 20 years of follow-up. International Journal of Cancer. Aug 1. 2006;119(3):687-94.
19 Crook PD, Jones ME, Hall AJ, et al. Mortality of hepatitis B surface antigen-positive blood donors in England and Wales. International Journal of Epidemiology. Feb. 2003;32(1):118-24. [pmid: 12690022].
20 Chan HL, Tse CH, Mo F, et al. High viral load and hepatitis B virus subgenotype ce are associated with increased risk of hepatocellular carcinoma. J Clin Oncol. Jan 10. 2008;26(2):177-82. [pmid: 18182659].
21 Chen JG, Kuang SY, Egner PA, et al. Acceleration to death from liver cancer in people with hepatitis B viral mutations detected in plasma by mass spectrometry. Cancer Epidemiology, Biomarkers & Prevention. Jun. 2007;16(6):1213-8.
22 Chen G, Lin W, Shen F, et al. Past HBV viral load as predictor of mortality and morbidity from HCC and chronic liver disease in a prospective study. American Journal of Gastroenterology. Aug. 2006;101(8):1797-803. [pmid: 16817842].
23 Chen G, Lin W, Shen F, et al. Chronic hepatitis B virus infection and mortality from non-liver causes: results from the Haimen City cohort study. International Journal of Epidemiology. Feb. 2005;34(1):132-7. [pmid: 15659459].
24 Evans AA, Chen G, Ross EA, et al. Eight-year follow-up of the 90,000-person Haimen City cohort: I. Hepatocellular carcinoma mortality, risk factors, and gender differences. Cancer Epidemiology, Biomarkers & Prevention. Apr. 2002;11(4):369-76.
25 London WT, Evans AA, McGlynn K, et al. Viral, host and environmental risk factors for hepatocellular carcinoma: a prospective study in Haimen City, China. Intervirology. 1995;38(34):155-61. [pmid: 8682610].
26 Chen CJ, Yang HI, Su J, et al. Risk of hepatocellular carcinoma across a biological gradient of serum hepatitis B virus DNA level. JAMA. Jan 4. 2006;295(1):65-73. [pmid: 16391218].
27 Iloeje UH, Yang HI, Su J, et al. Predicting cirrhosis risk based on the level of circulating hepatitis B viral load.[see comment]. Gastroenterology. Mar. 2006;130(3):678-86. [pmid: 16530509].
28 Yu MW, Yeh SH, Chen PJ, et al. Hepatitis B virus genotype and DNA level and hepatocellular carcinoma: a prospective study in men.[see comment]. Journal of the National Cancer Institute. Feb 16. 2005;97(4):265-72. [pmid: 15713961].
29 Yu MW, Yang SY, Chiu YH, et al. A p53 genetic polymorphism as a modulator of hepatocellular carcinoma risk in relation to chronic liver disease, familial tendency, and cigarette smoking in hepatitis B carriers. Hepatology. Mar. 1999;29(3):697-702. [pmid: 10051470].
30 Wang LY, You SL, Lu SN, et al. Risk of hepatocellular carcinoma and habits of alcohol drinking, betel quid chewing and cigarette smoking: a cohort of 2416 HBsAg-seropositive and 9421 HBsAg-seronegative male residents in Taiwan. Cancer Causes & Control. Apr. 2003;14(3):241-50. [pmid: 12814203].
31 Yang HI, Lu SN, Liaw YF, et al. Hepatitis B e antigen and the risk of hepatocellular carcinoma. New England Journal of Medicine. Jul 18. 2002;347(3):168-74. [pmid: 12124405].
32 Yuen MF, Yuan HJ, Wong DK, et al. Prognostic determinants for chronic hepatitis B in Asians: therapeutic implications. Gut. Nov. 2005;54(11):1610-4. [pmid: 15871997].
33 Jee SH, Ohrr H, Sull JW, et al. Cigarette smoking, alcohol drinking, hepatitis B, and risk for hepatocellular carcinoma in Korea. Journal of the National Cancer Institute. Dec 15. 2004;96(24):1851-6. [pmid: 15601641].
34 Lam CM, Chan AO, Ho P, et al. Different presentation of hepatitis B-related hepatocellular carcinoma in a cohort of 1863 young and old patients - implications for screening. Alimentary Pharmacology & Therapeutics. Apr 1. 2004;19(7):771-7. [pmid: 15043518].
35 Tanaka H, Tsukuma H, Yamano H, et al. Prospective study on the risk of hepatocellular carcinoma among hepatitis C virus-positive blood donors focusing on demographic factors, alanine aminotransferase level at donation and interaction with hepatitis B virus. International Journal of Cancer. Dec 20. 2004;112(6):1075-80.
36 Mori M, Hara M, Wada I, et al. Prospective study of hepatitis B and C viral infections, cigarette smoking, alcohol consumption, and other factors associated with hepatocellular carcinoma risk in Japan. American Journal of Epidemiology. Jan 15. 2000;151(2):131-9. [pmid: 10645815].
37 Yu MW, Hsu FC, Sheen IS, et al. Prospective study of hepatocellular carcinoma and liver cirrhosis in asymptomatic chronic hepatitis B virus carriers. American Journal of Epidemiology. Jun 1. 1997;145(11):1039-47. [pmid: 9169913].
38 Tokudome S, Ikeda M, Matsushita K, et al. Hepatocellular carcinoma among female Japanese hepatitis B virus carriers. Hepato-Gastroenterology. Dec. 1987;34(6):246-8. [pmid: 2828208].
39 Beasley RP, Hwang LY, Lin CC, et al. Hepatocellular carcinoma and hepatitis B virus. A prospective study of 22 707 men in Taiwan. Lancet. Nov 21. 1981;2(8256):1129-33. [pmid: 6118576].
40 Zeng M, Mao Y, Yao G, et al. A double-blind randomized trial of adefovir dipivoxil in Chinese subjects with HBeAg-positive chronic hepatitis B. Hepatology. Jul. 2006;44(1):108-16. [pmid: 16799983].
41 Hadziyannis SJ, Tassopoulos NC, Heathcote EJ, et al. Adefovir dipivoxil for the treatment of hepatitis B e antigen-negative chronic hepatitis B. N Engl J Med. Feb 27. 2003;348(9):800-7. [pmid: 12606734].
42 Marcellin P, Chang TT, Lim SG, et al. Adefovir dipivoxil for the treatment of hepatitis B e antigen-positive chronic hepatitis B. N Engl J Med. Feb 27. 2003;348(9):808-16. [pmid: 12606735].
43 Peters MG, Hann HwH, Martin P, et al. Adefovir dipivoxil alone or in combination with lamivudine in patients with lamivudine-resistant chronic hepatitis B. Gastroenterology. Jan. 2004;126(1):91-101. [pmid: 14699491].
44 Chan HL, Heathcote EJ, Marcellin P, et al. Treatment of hepatitis B e antigen positive chronic hepatitis with telbivudine or adefovir: a randomized trial. Ann Intern Med. Dec 4. 2007;147(11):745-54. [pmid: 17909201].
45 Akyildiz M, Gunsar F, Ersoz G, et al. Adefovir dipivoxil alone or in combination with lamivudine for three months in patients with lamivudine resistant compensated chronic hepatitis B. Dig Dis Sci. Dec. 2007;52(12):3444-7. [pmid: 17431777].
46 Chan HL, Wang H, Niu J, et al. Two-year lamivudine treatment for hepatitis B e antigen-negative chronic hepatitis B: a double-blind, placebo-controlled trial. Antivir Ther. 2007;12(3):345-53. [pmid: 17591024].
47 Schiff ER, Dienstag JL, Karayalcin S, et al. Lamivudine and 24 weeks of lamivudine/interferon combination therapy for hepatitis B e antigen-positive chronic hepatitis B in interferon nonresponders. J Hepatol. Jun. 2003;38(6):818-26. [pmid: 12763376].
48 Dienstag JL, Schiff ER, Wright TL, et al. Lamivudine as initial treatment for chronic hepatitis B in the United States. N Engl J Med. Oct 21. 1999;341(17):1256-63. [pmid: 10528035].
49 Tassopoulos NC, Volpes R, Pastore G, et al. Efficacy of lamivudine in patients with hepatitis B e antigen-negative/hepatitis B virus DNA-positive (precore mutant) chronic hepatitis B.Lamivudine Precore Mutant Study Group. Hepatology. Mar. 1999;29(3):889-96. [pmid: 10051494].
50 Lai CL, Chien RN, Leung NW, et al. A one-year trial of lamivudine for chronic hepatitis B. Asia Hepatitis Lamivudine Study Group. N Engl J Med. Jul 9. 1998;339(2):61-8. [pmid: 9654535].
51 Liaw YF, Sung JJ, Chow WC, et al. Lamivudine for patients with chronic hepatitis B and advanced liver disease. N Engl J Med. Oct 7. 2004;351(15):1521-31. [pmid: 15470215].
52 Jang JW, Choi JY, Bae SH, et al. A randomized controlled study of preemptive lamivudine in patients receiving transarterial chemo-lipiodolization. Hepatology. Feb. 2006;43(2):233-40. [pmid: 16440357].
53 Ke CZ, Chen Y, Gong ZJ, et al. Dynamic changes of HBV DNA in serum and peripheral blood mononuclear cells of chronic hepatitis patients after lamivudine treatment. World J Gastroenterol. Jul 7. 2006;12(25):4061-3. [pmid: 16810760].
54 Kim YJ, Kim BG, Jung JO, et al. High rates of progressive hepatic functional deterioration whether lamivudine therapy is continued or discontinued after emergence of a lamivudine-resistant mutant: a prospective randomized controlled study. J Gastroenterol. Mar. 2006;41(3):240-9. [pmid: 16699858].
55 Nevens F, Main J, Honkoop P, et al. Lamivudine therapy for chronic hepatitis B: a six-month randomized dose-ranging study. Gastroenterology. Oct. 1997;113(4):1258-63. [pmid: 9322520].
56 Lau GK, Piratvisuth T, Luo KX, et al. Peginterferon Alfa-2a, lamivudine, and the combination for HBeAg-positive chronic hepatitis B. N Engl J Med. Jun 30. 2005;352(26):2682-95. [pmid: 15987917].
57 Marcellin P, Lau GK, Bonino F, et al. Peginterferon alfa-2a alone, lamivudine alone, and the two in combination in patients with HBeAg-negative chronic hepatitis B. N Engl J Med. Sep 16. 2004;351(12):1206-17. [pmid: 15371578].
58 Perrillo R, Hann HW, Mutimer D, et al. Adefovir dipivoxil added to ongoing lamivudine in chronic hepatitis B with YMDD mutant hepatitis B virus. Gastroenterology. Jan. 2004;126(1):81-90. [pmid: 14699490].
59 Chan HL, Leung NW, Hui AY, et al. A randomized, controlled trial of combination therapy for chronic hepatitis B: comparing pegylated interferon-alpha2b and lamivudine with lamivudine alone. Ann Intern Med. Feb 15. 2005;142(4):240-50. [pmid: 15710957].
60 Akyuz F, Kaymakoglu S, Demir K, et al. Lamivudine monotherapy and lamivudine plus interferon alpha combination therapy in HBeAg negative chronic hepatitis B not responding to previous interferon alpha monotherapy. Acta Gastroenterol Belg. Jan–Mar. 2007;70(1):20-4. [pmid: 17619534].
61 Lu HY, Zhuang LW, Yu YY, et al. Intrahepatic HBV DNA as a predictor of antivirus treatment efficacy in HBeAg-positive chronic hepatitis B patients. World J Gastroenterol. May 28. 2007;13(20):2878-82. [pmid: 17569128].
62 Shi M, Wang RS, Zhang H, et al. Sequential treatment with lamivudine and interferon-alpha monotherapies in hepatitis B e antigen-negative Chinese patients and its suppression of lamivudine-resistant mutations. J Antimicrob Chemother. Nov. 2006;58(5):1031-5. [pmid: 16987866].
63 Economou M, Manolakopoulos S, Trikalinos TA, et al. Interferon-alpha plus lamivudine vs lamivudine reduces breakthroughs, but does not affect sustained response in HBeAg negative chronic hepatitis B. World J Gastroenterol. Oct 7. 2005;11(37):5882-7. [pmid: 16270403].
64 Akarca US, Ersoz G, Gunsar F, et al. Interferon-lamivudine combination is no better than lamivudine alone in anti-HBe-positive chronic hepatitis B. Antivir Ther. Jun. 2004;9(3):325-34. [pmid: 15259895].
65 Jang MK, Chung YH, Choi MH, et al. Combination of alpha-interferon with lamivudine reduces viral breakthrough during long-term therapy. J Gastroenterol Hepatol. Dec. 2004;19(12):1363-8. [pmid: 15610309].
66 Barbaro G, Zechini F, Pellicelli AM, et al. Long-term efficacy of interferon alpha-2b and lamivudine in combination compared to lamivudine monotherapy in patients with chronic hepatitis B. An Italian multicenter, randomized trial. J Hepatol. Sep. 2001;35(3):406-11. [pmid: 11592603].
67 Schalm SW, Heathcote J, Cianciara J, et al. Lamivudine and alpha interferon combination treatment of patients with chronic hepatitis B infection: a randomised trial. Gut. Apr. 2000;46(4):562-8. [pmid: 10716688].
68 Scotto G, Palumbo E, Fazio V, et al. Efficacy and tolerability of lamivudine alone versus lamivudine plus alpha-interferon for treatment of chronic active hepatitis B in patients with a precore-mutant variant. Infez Med. Sep. 2006;14(3):145-51. [pmid: 17127828].
69 Sarin SK, Kumar M, Kumar R, et al. Higher efficacy of sequential therapy with interferon-alpha and lamivudine combination compared to lamivudine monotherapy in HBeAg positive chronic hepatitis B patients. Am J Gastroenterol. Nov. 2005;100(11):2463-71. [pmid: 16279901].
70 Santantonio T, Niro GA, Sinisi E, et al. Lamivudine/interferon combination therapy in anti-HBe positive chronic hepatitis B patients: a controlled pilot study. J Hepatol. Jun. 2002;36(6):799-804. [pmid: 12044531].
71 Lai CL, Gane E, Liaw YF, et al. Telbivudine versus lamivudine in patients with chronic hepatitis B. N Engl J Med. Dec 20. 2007;357(25):2576-88. [pmid: 18094378].
72 Lai CL, Leung N, Teo EK, et al. A 1-year trial of telbivudine, lamivudine, and the combination in patients with hepatitis B e antigen-positive chronic hepatitis B. Gastroenterology. Aug. 2005;129(2):528-36. [pmid: 16083710].
73 Chang TT, Gish RG, de Man R, et al. A comparison of entecavir and lamivudine for HBeAg-positive chronic hepatitis B. N Engl J Med. Mar 9. 2006;354(10):1001-10. [pmid: 16525137].
74 Lai CL, Shouval D, Lok AS, et al. Entecavir versus lamivudine for patients with HBeAg-negative chronic hepatitis B. N Engl J Med. Mar 9. 2006;354(10):1011-20. [pmid: 16525138].
75 Sherman M, Yurdaydin C, Sollano J, et al. Entecavir for treatment of lamivudine-refractory, HBeAg-positive chronic hepatitis B. Gastroenterology. Jun. 2006;130(7):2039-49. [pmid: 16762627].
76 Chang TT, Gish RG, Hadziyannis SJ, et al. A dose-ranging study of the efficacy and tolerability of entecavir in Lamivudine-refractory chronic hepatitis B patients. Gastroenterology. Oct. 2005;129(4):1198-209. [pmid: 16230074].
77 Lai CL, Rosmawati M, Lao J, et al. Entecavir is superior to lamivudine in reducing hepatitis B virus DNA in patients with chronic hepatitis B infection. Gastroenterology. Dec. 2002;123(6):1831-8. [pmid: 12454840].
78 Janssen HL, van Zonneveld M, Senturk H, et al. Pegylated interferon alfa-2b alone or in combination with lamivudine for HBeAg-positive chronic hepatitis B: a randomised trial. Lancet. Jan 8–14. 2005;365(9454):123-9. [pmid: 15639293].
79 Yalcin K, Degertekin H, Yildiz F, et al. Comparison of 12-month courses of interferon-alpha-2b-lamivudine combination therapy and interferon-alpha-2b monotherapy among patients with untreated chronic hepatitis B. Clin Infect Dis. Jun 15. 2003;36(12):1516-22. [pmid: 12802750].
80 Mutimer D, Naoumov N, Honkoop P, et al. Combination alpha-interferon and lamivudine therapy for alpha-interferon-resistant chronic hepatitis B infection: results of a pilot study. J Hepatol. Jun. 1998;28(6):923-9. [pmid: 9672165].
81 Zhao H, Kurbanov F, Wan MB, et al. Genotype B and younger patient age associated with better response to low-dose therapy: a trial with pegylated/nonpegylated interferon-alpha-2b for hepatitis B e antigen-positive patients with chronic hepatitis B in China. Clin Infect Dis. Feb 15. 2007;44(4):541-8. [pmid: 17243057].
82 Chung YH, Song BC, Lee GC, et al. Individualization of interferon therapy using serum hepatitis B virus DNA to reduce viral relapse in patients with chronic hepatitis B: a randomized controlled trial. Eur J Gastroenterol Hepatol. May. 2003;15(5):489-93. [pmid: 12702905].
83 Janssen HL, Gerken G, Carreno V, et al. Interferon alfa for chronic hepatitis B infection: increased efficacy of prolonged treatment. The European Concerted Action on Viral Hepatitis (EUROHEP). Hepatology. Jul. 1999;30(1):238-43. [pmid: 10385662].
84 Lampertico P, Del Ninno E, Manzin A, et al. A randomized, controlled trial of a 24-month course of interferon alfa 2b in patients with chronic hepatitis B who had hepatitis B virus DNA without hepatitis B e antigen in serum. Hepatology. Dec. 1997;26(6):1621-5. [pmid: 9398007].
85 Lopez-Alcorocho JM, Bartolome J, Cotonat T, et al. Efficacy of prolonged interferon-alpha treatment in chronic hepatitis B patients with HBeAb: comparison between 6 and 12 months of therapy. J Viral Hepat. 1997;4(Suppl 1):27-32. [pmid: 9097275].
86 Di Bisceglie AM, Fong TL, Fried MW, et al. A randomized, controlled trial of recombinant alpha-interferon therapy for chronic hepatitis B. Am J Gastroenterol. Nov. 1993;88(11):1887-92. [pmid: 8237937].
87 Muller R, Baumgarten R, Markus R, et al. Treatment of chronic hepatitis B with interferon alfa-2b. J Hepatol. 1990;11(Suppl 1):S137-40. [pmid: 2079572].
88 Hadziyannis S, Bramou T, Makris A, et al. Interferon alfa-2b treatment of HBeAg negative/serum HBV DNA positive chronic active hepatitis type B. J Hepatol. 1990;11(Suppl 1):S133-6. [pmid: 2079571].
89 Waked I, Amin M, Abd el Fattah S, et al. Experience with interferon in chronic hepatitis B in Egypt. J Chemother. Oct. 1990;2(5):310-8. [pmid: 2090770].
90 Reichen J, Bianchi L, Frei PC, et al. Efficacy of steroid withdrawal and low-dose interferon treatment in chronic active hepatitis B. Results of a randomized multicenter trial. Swiss Association for the Study of the Liver. J Hepatol. Feb. 1994;20(2):168-74. [pmid: 8006396].
91 Zarski JP, Causse X, Cohard M, et al. A randomized, controlled trial of interferon alfa-2b alone and with simultaneous prednisone for the treatment of chronic hepatitis B. French Multicenter Group. J Hepatol. Jun. 1994;20(6):735-41. [pmid: 7930473].
92 Perez V, Findor J, Tanno H, et al. A controlled trial of high dose interferon, alone and after prednisone withdrawal, in the treatment of chronic hepatitis B: long term follow up. Gut. 1993;34(2 Suppl):S91-4. [pmid: 8314497].
93 Lok AS, Wu PC, Lai CL, et al. A controlled trial of interferon with or without prednisone priming for chronic hepatitis B. Gastroenterology. Jun. 1992;102(6):2091-7. [pmid: 1587429].
94 Niederau C, Heintges T, Niederau M, et al. Prospective randomized controlled trial of sequential treatment with corticoids and alpha-interferon versus treatment with interferon alone in patients with chronic active hepatitis B. Eur J Med. Nov. 1992;1(7):396-402. [pmid: 1341478].
95 Perez V, Tanno H, Villamil F, et al. Recombinant interferon alfa-2b following prednisone withdrawal in the treatment of chronic type B hepatitis. J Hepatol. 1990;11(Suppl 1):S113-7. [pmid: 2079567].
96 Perrillo RP, Schiff ER, Davis GL, et al. A randomized, controlled trial of interferon alfa-2b alone and after prednisone withdrawal for the treatment of chronic hepatitis B. The Hepatitis Interventional Therapy Group. N Engl J Med. Aug 2. 1990;323(5):295-301. [pmid: 2195346].
97 Hadziyannis SJ, Tassopoulos NC, Heathcote EJ, et al. Long-term therapy with adefovir dipivoxil for HBeAg-negative chronic hepatitis B for up to 5 years. Gastroenterology. Dec. 2006;131(6):1743-51. [pmid: 17087951].
98 Hadziyannis SJ, Tassopoulos NC, Heathcote EJ, et al. Long-term therapy with adefovir dipivoxil for HBeAg-negative chronic hepatitis B. N Engl J Med. Jun 30. 2005;352(26):2673-81. [pmid: 15987916].
99 Izzedine H, Hulot JS, Launay-Vacher V, et al. Renal safety of adefovir dipivoxil in patients with chronic hepatitis B: two double-blind, randomized, placebo-controlled studies. Kidney Int. Sep. 2004;66(3):1153-8. [pmid: 15327411].
100 Westland CE, Yang H, Delaney WEt, et al. Week 48 resistance surveillance in two phase 3 clinical studies of adefovir dipivoxil for chronic hepatitis B. Hepatology. Jul. 2003;38(1):96-103. [pmid: 12829991].
101 Gish RG, Lok AS, Chang TT, et al. Entecavir therapy for up to 96 weeks in patients with HBeAg-positive chronic hepatitis B. Gastroenterology. Nov. 2007;133(5):1437-44. [pmid: 17983800].
102 Wai CT, Chu CJ, Hussain M, et al. HBV genotype B is associated with better response to interferon therapy in HBeAg(+) chronic hepatitis than genotype C. Hepatology. Dec. 2002;36(6):1425-30. [pmid: 12447868].
103 Robson SC, Brice E, van Rensburg C, et al. Safety and efficacy of interferon alpha-2b following prednisone withdrawal in the treatment of chronic viral hepatitis B. A case-controlled, randomised study. S Afr Med J. Nov. 1992;82(5):317-20. [pmid: 1448711].
104 Perrillo RP, Lai CL, Liaw YF, et al. Predictors of HBeAg loss after lamivudine treatment for chronic hepatitis B. Hepatology. Jul. 2002;36(1):186-94. [pmid: 12085364].
105 Muller R, Baumgarten R, Markus R, et al. Low dose alpha interferon treatment in chronic hepatitis B virus infection. Gut. 1993;34(2 Suppl):S97-8. [pmid: 8314499].
106 Leung NW, Lai CL, Chang TT, et al. Extended lamivudine treatment in patients with chronic hepatitis B enhances hepatitis B e antigen seroconversion rates: results after 3 years of therapy. Hepatology. Jun. 2001;33(6):1527-32. [pmid: 11391543].
107 Dienstag JL, Goldin RD, Heathcote EJ, et al. Histological outcome during long-term lamivudine therapy. Gastroenterology. Jan. 2003;124(1):105-17. [pmid: 12512035].
108 Yao GB. Management of hepatitis B in China. J Med Virol. Jul. 2000;61(3):392-7. [pmid: 10861652].
109 Honkoop P, de Man RA, Niesters HG, et al. Quantitative hepatitis B virus DNA assessment by the limiting-dilution polymerase chain reaction in chronic hepatitis B patients: evidence of continuing viral suppression with longer duration and higher dose of lamivudine therapy. J Viral Hepat. Sep. 1998;5(5):307-12. [pmid: 9795914].
110 Liaw YF, Leung NW, Chang TT, et al. Effects of extended lamivudine therapy in Asian patients with chronic hepatitis B. Asia Hepatitis Lamivudine Study Group. Gastroenterology. Jul. 2000;119(1):172-80. [pmid: 10889166].
111 Yuen MF, Chow DH, Tsui K, et al. Liver histology of Asian patients with chronic hepatitis B on prolonged lamivudine therapy. Aliment Pharmacol Ther. Apr 1. 2005;21(7):841-9. [pmid: 15801919].
112 Yao G, Wang B, Cui Z, et al. A randomized double-blind placebo-controlled study of lamivudine in the treatment of patients with chronic hepatitis B virus infection. Chin Med J (Engl). May. 1999;112(5):387-91. [pmid: 11593504].
113 Kweon YO, Goodman ZD, Dienstag JL, et al. Decreasing fibrogenesis: an immunohistochemical study of paired liver biopsies following lamivudine therapy for chronic hepatitis B. J Hepatol. Dec. 2001;35(6):749-55. [pmid: 11738102].
114 Bonino F, Marcellin P, Lau GK, et al. Predicting response to peginterferon alpha-2a, lamivudine and the two combined for HBeAg-negative chronic hepatitis B. Gut. May. 2007;56(5):699-705. [pmid: 17127704].
115 Cindoruk M, Karakan T, Unal S. Hepatic steatosis has no impact on the outcome of treatment in patients with chronic hepatitis B infection. J Clin Gastroenterol. May–Jun. 2007;41(5):513-7. [pmid: 17450036].
116 Cooksley WG, Piratvisuth T, Lee SD, et al. Peginterferon alpha-2a (40 kDa): an advance in the treatment of hepatitis B e antigen-positive chronic hepatitis B. J Viral Hepat. Jul. 2003;10(4):298-305. [pmid: 12823597].
117 Chan HL, Hui AY, Wong VW, et al. Long-term follow-up of peginterferon and lamivudine combination treatment in HBeAg-positive chronic hepatitis B. Hepatology. Jun. 2005;41(6):1357-64. [pmid: 15880608].
118 Chan HL, Tse AM, Zhang MD, et al. Genetic polymorphisms of interleukin-1-beta in association with sustained response to anti-viral treatment in chronic hepatitis B in Chinese. Aliment Pharmacol Ther. Jun 15. 2006;23(12):1703-11. [pmid: 16817913].
119 van Zonneveld M, Flink HJ, Verhey E, et al. The safety of pegylated interferon alpha-2b in the treatment of chronic hepatitis B: predictive factors for dose reduction and treatment discontinuation. Aliment Pharmacol Ther. May 1. 2005;21(9):1163-71. [pmid: 15854180].
120 Flink HJ, Sprengers D, Hansen BE, et al. Flares in chronic hepatitis B patients induced by the host or the virus? Relation to treatment response during Peg-interferon {alpha}-2b therapy. Gut. Nov. 2005;54(11):1604-9. [pmid: 15923670].
121 Flink HJ, Hansen BE, Heathcote EJ, et al. Successful treatment with peginterferon alfa-2b of HBeAg-positive HBV non-responders to standard interferon or lamivudine. Am J Gastroenterol. Nov. 2006;101(11):2523-9. [pmid: 17029610].
122 Flink HJ, van Zonneveld M, Hansen BE, et al. Treatment with Peg-interferon alpha-2b for HBeAg-positive chronic hepatitis B: HBsAg loss is associated with HBV genotype. Am J Gastroenterol. Feb. 2006;101(2):297-303. [pmid: 16454834].
123 ter Borg MJ, van Zonneveld M, Zeuzem S, et al. Patterns of viral decline during PEG-interferon alpha-2b therapy in HBeAg-positive chronic hepatitis B: relation to treatment response. Hepatology. Sep. 2006;44(3):721-7. [pmid: 16941701].
124 Buster EH, Hansen BE, Buti M, et al. Peginterferon alpha-2b is safe and effective in HBeAg-positive chronic hepatitis B patients with advanced fibrosis. Hepatology. Aug. 2007;46(2):388-94. [pmid: 17604363].
125 van Zonneveld M, Zondervan PE, Cakaloglu Y, et al. Peg-interferon improves liver histology in patients with HBeAg-positive chronic hepatitis B: no additional benefit of combination with lamivudine. Liver Int. May. 2006;26(4):399-405. [pmid: 16629642].
126 Westland C, Delaney Wt, Yang H, et al. Hepatitis B virus genotypes and virologic response in 694 patients in phase III studies of adefovir dipivoxil. Gastroenterology. Jul. 2003;125(1):107-16. [pmid: 12851876].
127 Di Marco V, Lo Iacono O, Camma C, et al. The long-term course of chronic hepatitis B. Hepatology. Jul. 1999;30(1):257-64. [pmid: 10385664].
128 Brunetto MR, Oliveri F, Coco B, et al. Outcome of anti-HBe positive chronic hepatitis B in alpha-interferon treated and untreated patients: a long term cohort study. J Hepatol. Feb. 2002;36(2):263-70. [pmid: 11830339].
129 Hui CK, Leung N, Shek WH, et al. Changes in Liver Histology as a “Surrogate” End Point of Antiviral Therapy for Chronic HBV Can Predict Progression to Liver Complications. J Clin Gastroenterol. May/June. 2008;42(5):533-8. [pmid: 18344885].
130 Papatheodoridis GV, Dimou E, Dimakopoulos K, et al. Outcome of hepatitis B e antigen-negative chronic hepatitis B on long-term nucleos(t)ide analog therapy starting with lamivudine. Hepatology. Jul. 2005;42(1):121-9. [pmid: 15962291].
131 Papatheodoridis GV, Petraki K, Cholongitas E, et al. Impact of interferon-alpha therapy on liver fibrosis progression in patients with HBeAg-negative chronic hepatitis B. J Viral Hepat. Mar. 2005;12(2):199-206. [pmid: 15720536].
132 Lampertico P, Del Ninno E, Vigano M, et al. Long-term suppression of hepatitis B e antigen-negative chronic hepatitis B by 24-month interferon therapy. Hepatology. Apr. 2003;37(4):756-63. [pmid: 12668967].