# Appendix C. Technical Expert Panel Members and Affiliation

TEP Member | Affiliation
Miriam Alter, Ph.D. | University of Texas Medical Branch at Galveston
Gary Davis, M.D. | Baylor University Medical Center
Daryl Lau, M.D. | Harvard University
Michael Sorrell, M.D. | NIH Consensus Development Conference Chairperson
Myron J. Tong, Ph.D., M.D. | Huntington Medical Research Institute