# Appendix B. List of Excluded Studies

## Key Question 1

1 Aach RD, Aach RD. What a difference an antigen makes. Gastroenterology. Jul. 1982;83(1 Pt 1):146-9. Editorial. [pmid: 6281123].
2 Abdo AA, Al-Jarallah BM, Sanai FM, Hersi AS, Al-Swat K, Azzam NA, et al. Hepatitis B genotypes: relation to clinical outcome in patients with chronic hepatitis B in Saudi Arabia. World J Gastroenterol. Nov 21. 2006;12(43):7019-24. Not relevant outcomes. [pmid: 17109498].
3 Aggarwal R, Ghoshal UC, Naik SR, Aggarwal R, Ghoshal UC, Naik SR. Treatment of chronic hepatitis B with interferon-alpha: cost-effectiveness in developing countries. Natl Med J India. Nov–Dec. 2002;15(6):320-7. Not relevant outcomes. [pmid: 12540064].
4 Ahmed ME, al-Knaway B, al-Wabel AH, Malik GM, Foli AK, Ahmed ME, et al. Acute upper gastrointestinal bleeding in southern Saudi Arabia. J R Coll Physicians Lond. Jan–Feb. 1997;31(1):62-4. Not eligible exposure. [pmid: 9044201].
5 Alexopoulos CG, Vaslamatzis M, Hatzidimitriou G, Alexopoulos CG, Vaslamatzis M, Hatzidimitriou G. Prevalence of hepatitis B virus marker positivity and evolution of hepatitis B virus profile, during chemotherapy, in patients with solid tumours. Br J Cancer. Sep. 1999;81(1):69-74. Not relevant outcomes. [pmid: 10487614].
6 Andreone P, Biselli M, Gramenzi A, Cursaro C, Morelli MC, Sama C, et al. Efficacy of lamivudine therapy for advanced liver disease in patients with precore mutant hepatitis B virus infection awaiting liver transplantation. Transplantation. Oct 27. 2002;74(8):1119-24. Not relevant outcomes. [pmid: 12438957].
7 Andus T, Gross V, Holstege A, Ott M, Weber M, David M, et al. High concentrations of soluble tumor necrosis factor receptors in ascites. Hepatology. Sep. 1992;16(3):749-55. Not eligible exposure. [pmid: 1324217].
8 Anonymous. Prevention of liver cancer. World Health Organ Tech Rep Ser. 1983;691:1-30. Review. [pmid: 6314682].
9 Anonymous. Effect of interferon-alpha on progression of cirrhosis to hepatocellular carcinoma: a retrospective cohort study. International Interferon-alpha Hepatocellular Carcinoma Study Group. Lancet. May 23. 1998;351(9115):1535-9. Less than 1000 patients and not US study. [pmid: 10326535].
10 Anonymous. Treatment of chronic hepatitis B: interferon alfa first. Prescrire Int. Feb. 2001;10(51):17-21. Review. [pmid: 11503853].
11 Anonymous. Summaries for patients. Acute liver failure in the United States. Annals of Internal Medicine. Dec 17. 2002;137(12):I24. Review.
12 Anselmo DM, Ghobrial RM, Jung LC, Weaver M, Cao C, Saab S, et al. New era of liver transplantation for hepatitis B: a 17-year single-center experience. Ann Surg. May. 2002;235(5):611-9. discussion 9–20. Not eligible target population. [pmid: 11981206].
13 Arase Y, Ikeda K, Murashima N, Chayama K, Tsubota A, Koida I, et al. Time course of histological changes in patients with a sustained biochemical and virological response to corticosteroid withdrawal therapy for chronic hepatitis B. American Journal of Gastroenterology. Nov. 1999;94(11):3304-9. Not relevant outcomes. [pmid: 10566734].
14 Arase Y, Ikeda K, Suzuki F, Suzuki Y, Kobayashi M, Akuta N, et al. Comparison of interferon and lamivudine treatment in Japanese patients with HBeAg positive chronic hepatitis B. Journal of Medical Virology. Sep. 2007;79(9):1286-92. Not relevant outcomes. [pmid: 17607775].
15 Arnot R, Arnot R. The evolving efforts to control hepatitis B virus. Pediatr Infect Dis J. Jul. 1998;17(7 Suppl):S26-9. Review. [pmid: 9688096].
16 Asmuth DM, Busch MP, Laycock ME, Mohr BA, Kalish LA, van der Horst CM, et al. Hepatitis B and C viral load changes following initiation of highly active antiretroviral therapy (HAART) in patients with advanced HIV infection. Antiviral Res. Aug. 2004;63(2):123-31. Not relevant outcomes. [pmid: 15302141].
17 Awada A, Sullivan S, Palkar V, Sbeih F, Naufal R, Al Rajeh S, et al. Brain magnetic resonance imaging in non-alcoholic cirrhosis. Eur J Radiol. Dec 15. 1995;21(2):84-8. Not relevant outcomes. [pmid: 8850497].
18 Baltayiannis G, Katsanos K, Karayiannis P, Tsianos EV, Baltayiannis G, Katsanos K, et al. Interferon-alpha therapy in HBeAg-negative chronic hepatitis B: a long-term prospective study from north-western Greece. Alimentary Pharmacology & Therapeutics. Aug 1. 2006;24(3):525-33. Less than 1000 patients and not US study. [pmid: 16886919].
19 Bartlett AS, McCall JL, Koea JB, Holden A, Yeong ML, Gurusinghe N, et al. Liver resection for hepatocellular carcinoma in a hepatitis B endemic area. World Journal of Surgery. Sep. 2007;31(9):1775-81. Not eligible target population. [pmid: 17610112].
20 Beasley RP, Beasley RP. Hepatitis B virus. The major etiology of hepatocellular carcinoma. Cancer. May 15. 1988;61(10):1942-56. Review. [pmid: 2834034].
21 Bege T, Le Treut YP, Hardwigsen J, Ananian P, Richa H, Campan P, et al. Prognostic factors after resection for hepatocellular carcinoma in nonfibrotic or moderately fibrotic liver. A 116-case European series. J Gastrointest Surg. May. 2007;11(5):619-25. Not eligible target population. [pmid: 17468920].
22 Bell SJ, Lau A, Thompson A, Watson KJ, Demediuk B, Shaw G, et al. Chronic hepatitis B: recommendations for therapy based on the natural history of disease in Australian patients. J Clin Virol. Feb. 2005;32(2):122-7. Not relevant outcomes. [pmid: 15653414].
23 Bellentani S, Tiribelli C, Saccoccio G, Sodde M, Fratti N, De Martin C, et al. Prevalence of chronic liver disease in the general population of northern Italy: the Dionysos Study. Hepatology. Dec. 1994;20(6):1442-9. Not eligible target population. [pmid: 7982643].
24 Ben-Ari Z, Broida E, Kittai Y, Chagnac A, Tur-Kaspa R, Ben-Ari Z, et al. An open-label study of lamivudine for chronic hepatitis B in six patients with chronic renal failure before and after kidney transplantation. American Journal of Gastroenterology. Dec. 2000;95(12):3579-83. Not eligible target population. [pmid: 11151895].
25 Benvegnu L, Alberti A, Benvegnu L, Alberti A. Risk factors and prevention of hepatocellular carcinoma in HCV infection. Dig Dis Sci. Dec. 1996;41(12 Suppl):49S-55S. Not eligible target population. [pmid: 9011476].
26 Benvegnu L, Alberti A, Benvegnu L, Alberti A. Patterns of hepatocellular carcinoma development in hepatitis B virus and hepatitis C virus related cirrhosis. Antiviral Res. Nov. 2001;52(2):199-207. Less than 1000 patients and not US study. [pmid: 11672830].
27 Benvegnu L, Fattovich G, Noventa F, Tremolada F, Chemello L, Cecchetto A, et al. Concurrent hepatitis B and C virus infection and risk of hepatocellular carcinoma in cirrhosis. A prospective study. Cancer. Nov 1. 1994;74(9):2442-8. Less than 1000 patients and not US study. [pmid: 7922998].
28 Benvegnu L, Gios M, Boccato S, Alberti A, Benvegnu L, Gios M, et al. Natural history of compensated viral cirrhosis: a prospective study on the incidence and hierarchy of major complications. Gut. May. 2004;53(5):744-9. Less than 1000 patients and not US study. [pmid: 15082595].
29 Benvegnu L, Noventa F, Bernardinello E, Pontisso P, Gatta A, Alberti A, et al. Evidence for an association between the aetiology of cirrhosis and pattern of hepatocellular carcinoma development. Gut. Jan. 2001;48(1):110-5. Less than 1000 patients and not US study. [pmid: 11115831].
30 Benvegnu L, Noventa F, Chemello L, Fattovich G, Alberti A, Benvegnu L, et al. Prevalence and incidence of cholecystolithiasis in cirrhosis and relation to the etiology of liver disease. Digestion. 1997;58(3):293-8. Not relevant outcomes. [pmid: 9243126].
31 Beutels P, Musabaev EI, Van Damme P, Yasin T, Beutels P, Musabaev EI, et al. The disease burden of hepatitis B in Uzbekistan. J Infect. May. 2000;40(3):234-41. Not relevant outcomes. [pmid: 10908017].
32 Bhathal PS, Dwyer JM, Mackay IR, Mathews JD, Robson G, Strickland RG, et al. The spectrum of liver disease in an Australian teaching hospital. A prospective study of 205 patients. Med J Aust. Dec 15. 1973;2(24):1085-9. Less than 1000 patients and not US study. [pmid: 4775824].
33 Boettler T, Panther E, Bengsch B, Nazarova N, Spangenberg HC, Blum HE, et al. Expression of the interleukin-7 receptor alpha chain (CD127) on virus-specific CD8+ T cells identifies functionally and phenotypically defined memory T cells during acute resolving hepatitis B virus infection. Journal of Virology. Apr. 2006;80(7):3532-40. Not relevant outcomes. [pmid: 16537621].
34 Bolukbas C, Bolukbas FF, Kendir T, Akbayir N, Ince AT, Abut E, et al. The effectiveness of lamivudine treatment in cirrhotic patients with HBV precore mutations: a prospective, open-label study. Dig Dis Sci. Jul. 2006;51(7):1196-202. Less than 1000 patients and not US study. [pmid: 16944009].
35 Bonacini M, Louie S, Bzowej N, Wohl AR, Bonacini M, Louie S, et al. Survival in patients with HIV infection and viral hepatitis B or C: a cohort study. AIDS. Oct 21. 2004;18(15):2039-45. Not eligible target population. [pmid: 15577625].
36 Bondini S, Kallman J, Dan A, Younoszai Z, Ramsey L, Nader F, et al. Health-related quality of life in patients with chronic hepatitis B. Liver International. Oct. 2007;27(8):1119-25. Not relevant outcomes. [pmid: 17845541].
37 Boni C, Fisicaro P, Valdatta C, Amadei B, Di Vincenzo P, Giuberti T, et al. Characterization of hepatitis B virus (HBV)-specific T-cell dysfunction in chronic HBV infection. Journal of Virology. Apr. 2007;81(8):4215-25. Not relevant outcomes. [pmid: 17287266].
38 Bortolotti F, Cadrobbi P, Crivellaro C, Alberti A, Rugge M, Bertaggia A, et al. Changes in hepatitis Be antigen/antibody system in children with chronic hepatitis B virus infection. J Pediatr. Nov. 1983;103(5):718-22. Not eligible target population. [pmid: 6631598].
39 Bortolotti F, Calzia R, Cadrobbi P, Giacchini R, Ciravegna B, Armigliato M, et al. Liver cirrhosis associated with chronic hepatitis B virus infection in childhood. J Pediatr. Feb. 1986;108(2):224-7. Not eligible target population. [pmid: 3944707].
40 Bortolotti F, Guido M, Bartolacci S, Cadrobbi P, Crivellaro C, Noventa F, et al. Chronic hepatitis B in children after e antigen seroclearance: final report of a 29-year longitudinal study. Hepatology. Mar. 2006;43(3):556-62. Less than 1000 patients and not US study. [pmid: 16496323].
41 Branco F, Mattos AA, Coral GP, Vanderborght B, Santos DE, Franca P, et al. Occult hepatitis B virus infection in patients with chronic liver disease due to hepatitis C virus and hepatocellular carcinoma in Brazil. Arquivos de Gastroenterologia. Jan–Mar. 2007;44(1):58-63. Not relevant outcomes. [pmid: 17639185].
42 Brunetto MR, Oliveri F, Coco B, Leandro G, Colombatto P, Gorin JM, et al. Outcome of anti-HBe positive chronic hepatitis B in alpha-interferon treated and untreated patients: a long term cohort study. Journal of Hepatology. Feb. 2002;36(2):263-70. Less than 1000 patients and not US study. [pmid: 11830339].
43 Bruno R, Sacchi P, Puoti M, Maiocchi L, Patruno S, Carosi G, et al. Natural history of compensated viral cirrhosis in a cohort of patients with HIV infection. Journal of Acquired Immune Deficiency Syndromes: JAIDS. Nov 1. 2007;46(3):297-303. Less than 1000 patients and not US study.
44 Bukhtiari N, Hussain T, Iqbal M, Malik AM, Qureshi AH, Hussain A, et al. Hepatitis B and C single and co-infection in chronic liver disease and their effect on the disease pattern. JPMA J Pak Med Assoc. Apr. 2003;53(4):136-40. Not relevant outcomes. [pmid: 12776896].
45 Buti M, Esteban R, Jardi R, Allende H, Esteban JI, Genesca J, et al. Clinical and serological outcome of acute delta infection. Journal of Hepatology. Aug. 1987;5(1):59-64. Not eligible target population. [pmid: 3655311].
46 Buti M, Jardi R, Allende H, Cotrina M, Rodriguez F, Viladomiu L, et al. Chronic delta hepatitis: is the prognosis worse when associated with hepatitis C virus and human immunodeficiency virus infections?. Journal of Medical Virology. May. 1996;49(1):66-9. Not eligible target population. [pmid: 8732862].
47 Caccamo L, Agnelli F, Reggiani P, Maggi U, Donato MF, Gatti S, et al. Role of lamivudine in the posttransplant prophylaxis of chronic hepatitis B virus and hepatitis delta virus coinfection. Transplantation. May 27. 2007;83(10):1341-4. Not eligible target population. [pmid: 17519784].
48 Cadranel JF, Di Martino V, Dorent R, Bernard B, Hoang C, Myara A, et al. Effects of ursodeoxycholic acid (ursodiol) treatment on chronic viral hepatitis in heart transplant patients: results of a prospective, double-blind, placebo-randomized study. Transplantation. Apr 15. 2003;75(7):977-82. Not relevant outcomes. [pmid: 12698083].
49 Caronia S, Taylor K, Pagliaro L, Carr C, Palazzo U, Petrik J, et al. Further evidence for an association between non-insulin-dependent diabetes mellitus and chronic hepatitis C virus infection. Hepatology. Oct. 1999;30(4):1059-63. Not eligible target population. [pmid: 10498660].
50 Caselmann WH, Alt M, Caselmann WH, Alt M. Hepatitis C virus infection as a major risk factor for hepatocellular carcinoma. Journal of Hepatology. 1996;24(2 Suppl):61-6. Not eligible target population. [pmid: 8836891].
51 Chan HL, Chui AK, Lau WY, Chan FK, Hui AY, Rao AR, et al. Outcome of lamivudine resistant hepatitis B virus mutant post-liver transplantation on lamivudine monoprophylaxis. Clin Transplant. Jun. 2004;18(3):295-300. Not eligible target population. [pmid: 15142051].
52 Chan HL, Hui AY, Wong ML, Tse AM, Hung LC, Wong VW, et al. Genotype C hepatitis B virus infection is associated with an increased risk of hepatocellular carcinoma. Gut. Oct. 2004;53(10):1494-8. Less than 1000 patients and not US study. [pmid: 15361502].
53 Chan HL, Kwan AC, To KF, Lai ST, Chan PK, Leung WK, et al. Clinical significance of hepatic derangement in severe acute respiratory syndrome. World J Gastroenterol. Apr 14. 2005;11(14):2148-53. Not eligible exposure. [pmid: 15810082].
54 Chan HL, Tsang SW, Leung NW, Tse CH, Hui Y, Tam JS, et al. Occult HBV infection in cryptogenic liver cirrhosis in an area with high prevalence of HBV infection. American Journal of Gastroenterology. May. 2002;97(5):1211-5. Not relevant outcomes. [pmid: 12014730].
55 Chan HL, Tsang SW, Wong ML, Tse CH, Leung NW, Chan FK, et al. Genotype B hepatitis B virus is associated with severe icteric flare-up of chronic hepatitis B virus infection in Hong Kong. American Journal of Gastroenterology. Oct. 2002;97(10):2629-33. Not relevant outcomes. [pmid: 12385451].
56 Chan TM, Fang GX, Tang CS, Cheng IK, Lai KN, Ho SK, et al. Preemptive lamivudine therapy based on HBV DNA level in HBsAg-positive kidney allograft recipients. Hepatology. Nov. 2002;36(5):1246-52. Not relevant outcomes. [pmid: 12395336].
57 Chao SD, Roberts JP, Farr M, Yao FY, Chao SD, Roberts JP, et al. Short waitlist time does not adversely impact outcome following liver transplantation for hepatocellular carcinoma. Am J Transplant. Jun. 2007;7(6):1594-600. Not eligible exposure. [pmid: 17430396].
58 Chen CH, Chen YY, Chen GH, Yang SS, Tang HS, Lin HH, et al. Hepatitis B virus transmission and hepatocarcinogenesis: a 9 year retrospective cohort of 13676 relatives with hepatocellular carcinoma. Journal of Hepatology. Apr. 2004;40(4):653-9. Not relevant outcomes. [pmid: 15030982].
59 Chen CH, Hung CH, Lee CM, Hu TH, Wang JH, Wang JC, et al. Pre-S deletion and complex mutations of hepatitis B virus related to advanced liver disease in HBeAg-negative patients. Gastroenterology. Nov. 2007;133(5):1466-74. Less than 1000 patients and not US study. [pmid: 17915220].
60 Chen CH, Lee CM, Hung CH, Hu TH, Wang JH, Wang JC, et al. Clinical significance and evolution of core promoter and precore mutations in HBeAg-positive patients with HBV genotype B and C: a longitudinal study. Liver International. Aug. 2007;27(6):806-15. Less than 1000 patients and not US study. [pmid: 17617124].
61 Chen CH, Lee CM, Lu SN, Changchien CS, Eng HL, Huang CM, et al. Clinical significance of hepatitis B virus (HBV) genotypes and precore and core promoter mutations affecting HBV e antigen expression in Taiwan. J Clin Microbiol. Dec. 2005;43(12):6000-6. Not relevant outcomes. [pmid: 16333089].
62 Chen CH, Wang JT, Lee CZ, Sheu JC, Wang TH, Chen DS, et al. Quantitative detection of hepatitis B virus DNA in human sera by branched-DNA signal amplification. J Virol Methods. May. 1995;53(1):131-7. Not relevant outcomes. [pmid: 7635922].
63 Chen CJ, Yu MW, Liaw YF, Wang LW, Chiamprasert S, Matin F, et al. Chronic hepatitis B carriers with null genotypes of glutathione S-transferase M1 and T1 polymorphisms who are exposed to aflatoxin are at increased risk of hepatocellular carcinoma. Am J Hum Genet. Jul. 1996;59(1):128-34. Less than 1000 patients and not US study. [pmid: 8659516].
64 Chen CY, Lu CL, Chang FY, Huang YS, Lee FY, Lu RH, et al. The impact of chronic hepatitis B viral infection on gastrointestinal motility. Eur J Gastroenterol Hepatol. Sep. 2000;12(9):995-1000. Not relevant outcomes. [pmid: 11007135].
65 Chen PM, Fan S, Liu CJ, Hsieh RK, Liu JH, Chuang MW, et al. Complications of bone marrow transplantation in Chinese. Haematol Blood Transfus. 1990;33:712-4. Not eligible target population. [pmid: 2323672].
66 Chen YS, Wu ZW, He JQ, Yu J, Yang SG, Zhang YM, et al. The curative effect of ALSS on 1-month mortality in AoCLF patients after 72 to 120 hours. International Journal of Artificial Organs. Oct. 2007;30(10):906-14. Not relevant outcomes. [pmid: 17992652].
67 Cheng AY, Kong AP, Wong VW, So WY, Chan HL, Ho CS, et al. Chronic hepatitis B viral infection independently predicts renal outcome in type 2 diabetic patients. Diabetologia. Aug. 2006;49(8):1777-84. Not relevant outcomes. [pmid: 16736132].
68 Chiaramonte M, Stroffolini T, Vian A, Stazi MA, Floreani A, Lorenzoni U, et al. Rate of incidence of hepatocellular carcinoma in patients with compensated viral cirrhosis. Cancer. May 15. 1999;85(10):2132-7. Less than 1000 patients and not US study. [pmid: 10326690].
69 Chiba T, Matsuzaki Y, Abei M, Shoda J, Tanaka N, Osuga T, et al. The role of previous hepatitis B virus infection and heavy smoking in hepatitis C virus-related hepatocellular carcinoma. American Journal of Gastroenterology. Jun. 1996;91(6):1195-203. Not eligible target population. [pmid: 8651170].
70 Chiesa R, Donato F, Tagger A, Favret M, Ribero ML, Nardi G, et al. Etiology of hepatocellular carcinoma in Italian patients with and without cirrhosis. Cancer Epidemiol Biomarkers Prev. Feb. 2000;9(2):213-6. Not eligible target population. [pmid: 10698484].
71 Chow KM, Law MC, Leung CB, Szeto CC, Li PK, Chow KM, et al. Antibody response to hepatitis B vaccine in end-stage renal disease patients. Nephron. 2006;103(3):c89-93. Not eligible target population. [pmid: 16534237].
72 Chu CM, Chang KY, Liaw YF, Chu CM, Chang KY, Liaw YF. Prevalence and prognostic significance of bacterascites in cirrhosis with ascites. Dig Dis Sci. Mar. 1995;40(3):561-5. Not relevant outcomes. [pmid: 7895544].
73 Chu CM, Hung SJ, Lin J, Tai DI, Liaw YF, Chu CM, et al. Natural history of hepatitis B e antigen to antibody seroconversion in patients with normal serum aminotransferase levels. Am J Med. Jun 15. 2004;116(12):829-34. Less than 1000 patients and not US study. [pmid: 15178498].
74 Chu CM, Liaw YF, Chu CM, Liaw YF. Genotype C hepatitis B virus infection is associated with a higher risk of reactivation of hepatitis B and progression to cirrhosis than genotype B: a longitudinal study of hepatitis B e antigen-positive patients with normal aminotransferase levels at baseline. Journal of Hepatology. Sep. 2005;43(3):411-7. Less than 1000 patients and not US study. [pmid: 16006001].
75 Chu CM, Yeh CT, Liaw YF, Chu CM, Yeh CT, Liaw YF. Fulminant hepatic failure in acute hepatitis C: increased risk in chronic carriers of hepatitis B virus. Gut. Oct. 1999;45(4):613-7. Not eligible target population. [pmid: 10486374].
76 Chung RT, Feng S, Delmonico FL, Chung RT, Feng S, Delmonico FL. Approach to the management of allograft recipients following the detection of hepatitis B virus in the prospective organ donor. Am J Transplant. Jul. 2001;1(2):185-91. Review. [pmid: 12099368].
77 Chung YH, Di Bisceglie AM, McMahon BJ, Lanier AP, Harpster A, Alter MJ, et al. Hepatocellular carcinoma not related to hepatitis B virus infection among Alaska natives. Int J Circumpolar Health. Jul. 1999;58(3):208-13. Not relevant outcomes. [pmid: 10528471].
78 Clement F, Dewint P, Leroux-Roels G. Evaluation of a new rapid test for the combined detection of hepatitis B virus surface antigen and hepatitis B virus e antigen. J Clin Microbiol. Dec. 2002;40(12):4603-6. Not relevant outcomes. [pmid: 12454159].
79 Cobden I, Bassendine MF, James OF, Cobden I, Bassendine MF, James OF. Hepatocellular carcinoma in north-east England: importance of hepatitis B infection and ex-tropical military service. Q J Med. Sep. 1986;60(233):855-63. Not relevant outcomes. [pmid: 2819931].
80 Colombo M, Donato MF, Colombo M, Donato MF. Prevention of hepatocellular carcinoma. Semin Liver Dis. 2005;25(2):155-61. Review. [pmid: 15918144].
81 Colombo M, Sangiovanni A, Colombo M, Sangiovanni A. The European approach to hepatocellular carcinoma. Hepato-Gastroenterology. Jan–Feb. 2002;49(43):12-6. Review. [pmid: 11941934].
82 Comunale MA, Mattu TS, Lowman MA, Evans AA, London WT, Semmes OJ, et al. Comparative proteomic analysis of de-N-glycosylated serum from hepatitis B carriers reveals polypeptides that correlate with disease status. Proteomics. Mar. 2004;4(3):826-38. Not relevant outcomes. [pmid: 14997503].
83 Coppola N, De Stefano G, Marrocco C, Scarano F, Scolastico C, Tarantino L, et al. Helicobacter spp. and liver diseases. Infez Med. Dec. 2003;11(4):201-7. Not eligible target population. [pmid: 14988668].
84 Curley SA, Izzo F, Gallipoli A, de Bellis M, Cremona F, Parisi V, et al. Identification and screening of 416 patients with chronic hepatitis at high risk to develop hepatocellular cancer. Ann Surg. Sep. 1995;222(3):375-80. discussion 80–3. Not relevant outcomes. [pmid: 7677466].
85 Da Villa G, Da Villa G. Successful mass vaccination against hepatitis B virus in a hyperendemic area in Italy. Res Virol. Jul–Aug. 1993;144(4):255-8. Not eligible target population. [pmid: 8210705].
86 Dan YY, Wai CT, Lee YM, Sutedja DS, Seet BL, Lim SG, et al. Outcome of lamivudine-resistant hepatitis B virus is generally benign except in cirrhotics. World J Gastroenterol. Jul 28. 2005;11(28):4344-50. Less than 1000 patients and not US study. [pmid: 16038032].
87 David-Neto E, Americo da Fonseca J, Jota de Paula F, Nahas WC, Sabbaga E, Ianhez LE, et al. The impact of azathioprine on chronic viral hepatitis in renal transplantation: a long-term, single-center, prospective study on azathioprine withdrawal. Transplantation. Oct 15. 1999;68(7):976-80. Not eligible target population. [pmid: 10532537].
88 de Franchis R, Meucci G, Vecchi M, Tatarella M, Colombo M, Del Ninno E, et al. The natural history of asymptomatic hepatitis B surface antigen carriers. Annals of Internal Medicine. Feb 1. 1993;118(3):191-4. Less than 1000 patients and not US study. [pmid: 8417636].
89 de Jongh FE, Janssen HL, de Man RA, Hop WC, Schalm SW, van Blankenstein M, et al. Survival and prognostic indicators in hepatitis B surface antigen-positive cirrhosis of the liver. Gastroenterology. Nov. 1992;103(5):1630-5. Less than 1000 patients and not US study. [pmid: 1426884].
90 Degertekin H, Yalcin K, Yakut M, Yurdaydin C. Seropositivity for delta hepatitis in patients with chronic hepatitis B and liver cirrhosis in Turkey: a meta-analysis. Liver International. Apr. 2008;28(4):494-8. Not relevant outcomes. [pmid: 18339076].
91 Degos F, Lugassy C, Degott C, Debure A, Carnot F, Theirs V, et al. Hepatitis B virus and hepatitis B-related viral infection in renal transplant recipients. A prospective study of 90 patients. Gastroenterology. Jan. 1988;94(1):151-6. Not relevant outcomes. [pmid: 3275563].
92 del Olmo JA, Serra MA, Rodriguez F, Escudero A, Gilabert S, Rodrigo JM, et al. Incidence and risk factors for hepatocellular carcinoma in 967 patients with cirrhosis. Journal of Cancer Research & Clinical Oncology. 1998;124(10):560-4. Not eligible target population. [pmid: 9829860].
93 Di Franco MJ, Zaknun D, Zaknun J, Vuja E, Oswald HP, Mayersbach P, et al. A prospective study of the association of serum neopterin, beta 2-microglobulin, and hepatitis B surface antigenemia with death in infants and children with HIV-1 disease. J Acquir Immune Defic Syndr. Oct. 1994;7(10):1079-85. Not eligible target population. [pmid: 8083826].
94 Di Marco V, Di Stefano R, Ferraro D, Almasio PL, Bonura C, Giglio M, et al. HBV-DNA suppression and disease course in HBV cirrhosis patients on long-term lamivudine therapy. Antiviral Therapy. 2005;10(3):431-9. Less than 1000 patients and not US study. [pmid: 15918334].
95 Di Marco V, Lo Iacono O, Camma C, Vaccaro A, Giunta M, Martorana G, et al. The long-term course of chronic hepatitis B. Hepatology. Jul. 1999;30(1):257-64. Less than 1000 patients and not US study. [pmid: 10385664].
96 Di Martino V, Thevenot T, Colin JF, Boyer N, Martinot M, Degos F, et al. Influence of HIV infection on the response to interferon therapy and the long-term outcome of chronic hepatitis B. Gastroenterology. Dec. 2002;123(6):1812-22. Less than 1000 patients and not US study. [pmid: 12454838].
97 Diamondstone LS, Aledort LM, Goedert JJ, Diamondstone LS, Aledort LM. Multicentre Hemophilia Cohort S, et al. Factors predictive of death among HIV-uninfected persons with haemophilia and other congenital coagulation disorders. Haemophilia. Sep. 2002;8(5):660-7. Not eligible target population. [pmid: 12199676].
98 Diamondstone LS, Blakley SA, Rice JC, Clark RA, Goedert JJ, Diamondstone LS, et al. Prognostic factors for all-cause mortality among hemophiliacs infected with human immunodeficiency virus. Am J Epidemiol. Aug 1. 1995;142(3):304-13. Not eligible target population. [pmid: 7631634].
99 Dickinson JA, Wun YT, Wong SL, Dickinson JA, Wun YT, Wong SL. Modelling death rates for carriers of hepatitis B. Epidemiol Infect. Feb. 2002;128(1):83-92. Not eligible exposure. [pmid: 11895095].
100 Dickson RC, Terrault NA, Ishitani M, Reddy KR, Sheiner P, Luketic V, et al. Protective antibody levels and dose requirements for IV 5% Nabi Hepatitis B immune globulin combined with lamivudine in liver transplantation for hepatitis B-induced end stage liver disease. Liver Transpl. Jan. 2006;12(1):124-33. Not relevant outcomes. [pmid: 16382463].
101 Dinc H, Kapiciolu S, Cihanyurdu N, Can G, Unal M, Topkaya L, et al. Effect of verapamil on portal and splanchnic hemodynamics in patients with advanced posthepatitic cirrhosis using duplex Doppler ultrasound. Eur J Radiol. Sep. 1996;23(2):97-101. Not eligible target population. [pmid: 8886716].
102 Dominguez M, Barcena R, Garcia M, Lopez-Sanroman A, Nuno J, Dominguez M, et al. Vaccination against hepatitis B virus in cirrhotic patients on liver transplant waiting list. Liver Transpl. Jul. 2000;6(4):440-2. Not eligible exposure. [pmid: 10915165].
103 Donato MF, Arosio E, Monti V, Fasani P, Prati D, Sangiovanni A, et al. Proliferating cell nuclear antigen assessed by a computer-assisted image analysis system in patients with chronic viral hepatitis and cirrhosis. Dig Liver Dis. Mar. 2002;34(3):197-203. Not relevant outcomes. [pmid: 11990392].
104 Douglas KC, Rush DR, O'Dell M, Monroe A, Ausmus M, Douglas KC, et al. Adult immunization in a network of family practice residency programs. J Fam Pract. Nov. 1990;31(5):513-20. Not eligible exposure. [pmid: 2230676].
105 Dumortier J, Chevallier P, Scoazec JY, Berger F, Boillot O, Dumortier J, et al. Combined lamivudine and hepatitis B immunoglobulin for the prevention of hepatitis B recurrence after liver transplantation: long-term results. Am J Transplant. Aug. 2003;3(8):999-1002. Not eligible target population. [pmid: 12859536].
106 Dunn C, Brunetto M, Reynolds G, Christophides T, Kennedy PT, Lampertico P, et al. Cytokines induced during chronic hepatitis B virus infection promote a pathway for NK cell-mediated liver damage. J Exp Med. Mar 19. 2007;204(3):667-80. Not relevant outcomes. [pmid: 17353365].
107 Durantel D, Carrouee-Durantel S, Werle-Lapostolle B, Brunelle MN, Pichoud C, Trepo C, et al. A new strategy for studying in vitro the drug susceptibility of clinical isolates of human hepatitis B virus. Hepatology. Oct. 2004;40(4):855-64. Not relevant outcomes. [pmid: 15382118].
108 Dusheiko GM, Brink BA, Conradie JD, Marimuthu T, Sher R, Dusheiko GM, et al. Regional prevalence of hepatitis B, delta, and human immunodeficiency virus infection in southern Africa: a large population survey. Am J Epidemiol. Jan. 1989;129(1):138-45. Not relevant outcomes. [pmid: 2462788].
109 Dusheiko GM, Roberts JA, Dusheiko GM, Roberts JA. Treatment of chronic type B and C hepatitis with interferon alfa: an economic appraisal. Hepatology. Dec. 1995;22(6):1863-73. Not relevant outcomes. [pmid: 7489999].
110 Elefsiniotis IS, Diamantis ID, Dourakis SP, Kafiri G, Pantazis K, Mavrogiannis C, et al. Anticardiolipin antibodies in chronic hepatitis B and chronic hepatitis D infection, and hepatitis B-related hepatocellular carcinoma. Relationship with portal vein thrombosis. Eur J Gastroenterol Hepatol. Jul. 2003;15(7):721-6. Not relevant outcomes. [pmid: 12811301].
111 El-Reshaid K, Johny KV, Sugathan TN, Hakim A, Georgous M, Nampoory MR, et al. End-stage renal disease and renal replacement therapy in Kuwait—epidemiological profile over the past 4 1/2 years. Nephrol Dial Transplant. 1994;9(5):532-8. Not eligible target population. [pmid: 8090333].
112 El-Sayed MH, Mohamed MM, Karim A, Maina AM, Oliveri F, Brunetto MR, et al. Severe liver disease is caused by HBV rather than HCV in children with hematological malignancies. Hematol J. 2003;4(5):321-7. Not eligible target population. [pmid: 14502256].
113 Englund M, Berg U, Tyden G, Englund M, Berg U, Tyden G. A longitudinal study of children who received renal transplants 10–20 years ago. Transplantation. Jul 27. 2003;76(2):311-8. Not eligible target population. [pmid: 12883184].
114 Enriquez AD, Campbell MS, Reddy KR. Cost-effectiveness of suppressing hepatitis B virus DNA in immune tolerant patients to prevent hepatocellular carcinoma and cirrhosis. Alimentary Pharmacology & Therapeutics. Aug 1. 2007;26(3):383-91. Not relevant outcomes. [pmid: 17635373].
115 Eriksen EM, Perlman JA, Miller A, Marcy SM, Lee H, Vadheim C, et al. Lack of association between hepatitis B birth immunization and neonatal death: a population-based study from the vaccine safety datalink project. Pediatr Infect Dis J. Jul. 2004;23(7):656-62. Not eligible target population. [pmid: 15247605].
116 Evans AA, O'Connell AP, Pugh JC, Mason WS, Shen FM, Chen GC, et al. Geographic variation in viral load among hepatitis B carriers with differing risks of hepatocellular carcinoma. Cancer Epidemiol Biomarkers Prev. Jul. 1998;7(7):559-65. Not relevant outcomes. [pmid: 9681522].
117 Fabrizi F, Bunnapradist S, Lunghi G, Aucella F, Martin P, Fabrizi F, et al. Epidemiology and clinical significance of hepatotropic infections in dialysis patients. Recent evidence. Minerva Urol Nefrol. Sep. 2004;56(3):249-57. Review. [pmid: 15467503].
118 Fabrizi F, Martin P, Dixit V, Kanwal F, Dulai G, Fabrizi F, et al. HBsAg seropositive status and survival after renal transplantation: meta-analysis of observational studies. Am J Transplant. Dec. 2005;5(12):2913-21. Not relevant outcomes. [pmid: 16303005].
119 Fabrizio F, Bunnapradist S, Martin P, Fabrizio F, Bunnapradist S, Martin P. Transplanting kidneys from donors with prior hepatitis B infection: one response to the organ shortage. Jn, J. Nov–Dec. 2002;15(6):605-13. Not relevant outcomes.
120 Fagan EA, Harrison TJ, Fagan EA, Harrison TJ. Exclusion in liver by polymerase chain reaction of hepatitis B and C viruses in acute liver failure attributed to sporadic non-A, non-B hepatitis. Journal of Hepatology. Oct. 1994;21(4):587-91. Not relevant outcomes. [pmid: 7814806].
121 Fagiuoli S, Minniti F, Pevere S, Farinati F, Burra P, Livi U, et al. HBV and HCV infections in heart transplant recipients. J Heart Lung Transplant. Jul. 2001;20(7):718-24. Not relevant outcomes. [pmid: 11448796].
122 Fan WM, Zhu WF, Yin LM, Wei L, Xu XY, Zhuang H, et al. Prospective study in 142 cases of hepatitis C virus infection. World J Gastroenterol. Oct 1. 2004;10(19):2867-9. Not eligible exposure. [pmid: 15334688].
123 Fargion S, Fracanzani AL, Piperno A, Braga M, D'Alba R, Ronchi G, et al. Prognostic factors for hepatocellular carcinoma in genetic hemochromatosis. Hepatology. Dec. 1994;20(6):1426-31. Not eligible target population. [pmid: 7982640].
124 Fasani P, Sangiovanni A, De Fazio C, Borzio M, Bruno S, Ronchi G, et al. High prevalence of multinodular hepatocellular carcinoma in patients with cirrhosis attributable to multiple risk factors. Hepatology. Jun. 1999;29(6):1704-7. Not eligible target population. [pmid: 10347111].
125 Fattovich G, Brollo L, Giustina G, Noventa F, Pontisso P, Alberti A, et al. Natural history and prognostic factors for chronic hepatitis type B. Gut. Mar. 1991;32(3):294-8. Less than 1000 patients and not US study. [pmid: 2013423].
126 Fattovich G, Fattovich G. Progression of hepatitis B and C to hepatocellular carcinoma in Western countries. Hepato-Gastroenterology. Aug. 1998;45(Suppl 3):1206-13. Review. [pmid: 9730376].
127 Fattovich G, Giustina G, Sanchez-Tapias J, Quero C, Mas A, Olivotto PG, et al. Delayed clearance of serum HBsAg in compensated cirrhosis B: relation to interferon alpha therapy and disease prognosis. European Concerted Action on Viral Hepatitis (EUROHEP). American Journal of Gastroenterology. Jun. 1998;93(6):896-900. Less than 1000 patients and not US study. [pmid: 9647014].
128 Fattovich G, Olivari N, Pasino M, D'Onofrio M, Martone E, Donato F. Long-term outcome of chronic hepatitis B in Caucasian patients: mortality after 25 years. Gut. Jan. 2008;57(1):84-90. Less than 1000 patients and not US study. [pmid: 17715267].
129 Fattovich G, Pantalena M, Zagni I, Realdi G, Schalm SW, Christensen E, et al. Effect of hepatitis B and C virus infections on the natural history of compensated cirrhosis: a cohort study of 297 patients. American Journal of Gastroenterology. Nov. 2002;97(11):2886-95. Not eligible target population. [pmid: 12425564].
130 Fattovich G, Rugge M, Brollo L, Pontisso P, Noventa F, Guido M, et al. Clinical, virologic and histologic outcome following seroconversion from HBeAg to anti-HBe in chronic hepatitis type B. Hepatology. Mar–Apr. 1986;6(2):167-72. Not relevant outcomes. [pmid: 3957228].
131 Fattovich G, Stroffolini T, Zagni I, Donato F, Fattovich G, Stroffolini T, et al. Hepatocellular carcinoma in cirrhosis: incidence and risk factors. Gastroenterology. Nov. 2004;127(5 Suppl 1):S35-50. Review. [pmid: 15508101].
132 Feinman SV, Berris B, Cooter N, Sinclair JC, Wrobel DM, Feinman SV, et al. Results of long-term prospective study of the hepatitis B surface antigen (HBsAg) carrier state. Hepato-Gastroenterology. Apr. 1982;29(2):58-61. Not relevant outcomes. [pmid: 7084885].
133 Fernandez E, Betriu MA, Gomez R, Montoliu J, Fernandez E, Betriu MA, et al. Response to the hepatitis B virus vaccine in haemodialysis patients: influence of malnutrition and its importance as a risk factor for morbidity and mortality. Nephrol Dial Transplant. Aug. 1996;11(8):1559-63. Not eligible exposure. [pmid: 8856211].
134 Fontana RJ, Hann HW, Perrillo RP, Vierling JM, Wright T, Rakela J, et al. Determinants of early mortality in patients with decompensated chronic hepatitis B treated with antiviral therapy. Gastroenterology. Sep. 2002;123(3):719-27. Not eligible target population. [pmid: 12198698].
135 Fontana RJ, Keeffe EB, Carey W, Fried M, Reddy R, Kowdley KV, et al. Effect of lamivudine treatment on survival of 309 North American patients awaiting liver transplantation for chronic hepatitis B. Liver Transpl. May. 2002;8(5):433-9. Not eligible target population. [pmid: 12004342].
136 Frilling A, Malago M, Broelsch CE, Frilling A, Malago M, Broelsch CE. Current status of liver transplantation for treatment of hepatocellular carcinoma. Dig Dis. 2001;19(4):333-7. Review. [pmid: 11935093].
137 Fujioka S, Shimomura H, Iwasaki Y, Fujio K, Nakagawa H, Onishi Y, et al. Hepatitis B virus gene in liver tissue promotes hepatocellular carcinoma development in chronic hepatitis C patients. Dig Dis Sci. Oct. 2003;48(10):1920-4. Not relevant outcomes. [pmid: 14627334].
138 Fujisawa T, Komatsu H, Inui A, Sogo T, Miyagawa Y, Fujitsuka S, et al. Long-term outcome of chronic hepatitis B in adolescents or young adults in follow-up from childhood. J Pediatr Gastroenterol Nutr. Feb. 2000;30(2):201-6. Not relevant outcomes. [pmid: 10697141].
139 Fujiwara K, Tanaka Y, Paulon E, Orito E, Sugiyama M, Ito K, et al. Novel type of hepatitis B virus mutation: replacement mutation involving a hepatocyte nuclear factor 1 binding site tandem repeat in chronic hepatitis B virus genotype E. Journal of Virology. Nov. 2005;79(22):14404-10. Not relevant outcomes. [pmid: 16254374].
140 Fukuhara T, Sharp GB, Mizuno T, Itakura H, Yamamoto M, Tokunaga M, et al. Liver cancer in atomic-bomb survivors: histological characteristics and relationships to radiation and hepatitis B and C viruses. J Radiat Res (Tokyo). Jun. 2001;42(2):117-30. Not relevant outcomes. [pmid: 11599879].
141 Gaeta GB, Stornaiuolo G, Precone DF, Lobello S, Chiaramonte M, Stroffolini T, et al. Epidemiological and clinical burden of chronic hepatitis B virus/hepatitis C virus infection. A multicenter Italian study. Journal of Hepatology. Dec. 2003;39(6):1036-41. Not relevant outcomes. [pmid: 14642623].
142 Ganne-Carrie N, Williams V, Kaddouri H, Trinchet JC, Dziri-Mendil S, Alloui C, et al. Significance of hepatitis B virus genotypes A to E in a cohort of patients with chronic hepatitis B in the Seine Saint Denis District of Paris (France). Journal of Medical Virology. Mar. 2006;78(3):335-40. Not relevant outcomes. [pmid: 16419113].
143 Garcia de Ancos JL, Roberts JA, Dusheiko GM, Garcia de Ancos JL, Roberts JA, Dusheiko GM. An economic evaluation of the costs of alpha-interferon treatment of chronic active hepatitis due to hepatitis B or C virus. Journal of Hepatology. 1990;11(Suppl 1):S11-8. Not eligible target population. [pmid: 2127784].
144 Garcia G, Hollinger FB, Garcia G, Hollinger FB. Hepatitis B virus infection and renal transplantation. Hepatology. Sep–Oct. 1988;8(5):1172-4. Not eligible target population. [pmid: 3047040].
145 Gennari L, Mazzaferro V, Regalia E, Colella G, Doci R, Bozzetti F, et al. Reappraisal of the role of liver transplantation in the treatment of hepatocellular carcinoma arising in cirrhosis. J Surg Oncol Suppl. 1993;3:83-6. Not eligible target population. [pmid: 7684917].
146 Ginsberg GM, Berger S, Shouval D, Ginsberg GM, Berger S, Shouval D. Cost-benefit analysis of a nationwide inoculation programme against viral hepatitis B in an area of intermediate endemicity. Bull World Health Organ. 1992;70(6):757-67. Not eligible exposure. [pmid: 1486673].
147 Ginsberg GM, Shouval D, Ginsberg GM, Shouval D. Cost-benefit analysis of a nationwide neonatal inoculation programme against hepatitis B in an area of intermediate endemicity. J Epidemiol Community Health. Dec. 1992;46(6):587-94. Not eligible exposure. [pmid: 1494073].
148 Goedert JJ, Eyster ME, Lederman MM, Mandalaki T, De Moerloose P, White GC 2nd, et al. End-stage liver disease in persons with hemophilia and transfusion-associated infections. Blood. Sep 1. 2002;100(5):1584-9. Not relevant outcomes. [pmid: 12176875].
149 Goldstein ST, Zhou F, Hadler SC, Bell BP, Mast EE, Margolis HS, et al. A mathematical model to estimate global hepatitis B disease burden and vaccination impact. International Journal of Epidemiology. Dec. 2005;34(6):1329-39. Not relevant outcomes. [pmid: 16249217].
150 Gore SM, Brettle RP, Burns SM, Lewis SC, Gore SM, Brettle RP, et al. Pilot study to estimate survivors to 1995 of 1983-1984 prevalent hepatitis C infections in Lothian patients who tested positive or negative for hepatitis B surface antigen in 1983-1984. J Infect. Sep. 1998;37(2):159-65. Not eligible exposure. [pmid: 9821091].
151 Guillevin L, Lhote F, Gayraud M, Cohen P, Jarrousse B, Lortholary O, et al. Prognostic factors in polyarteritis nodosa and Churg-Strauss syndrome. A prospective study in 342 patients. Medicine. Jan. 1996;75(1):17-28. Not eligible target population. [pmid: 8569467].
152 Guillevin L, Lhote F, Guillevin L, Lhote F. Treatment of polyarteritis nodosa and Churg-Strauss syndrome: indications of plasma exchanges. Transfus Sci. Dec. 1994;15(4):371-88. Not relevant outcomes. [pmid: 10155556].
153 Guillevin L, Lhote F, Leon A, Fauvelle F, Vivitski L, Trepo C, et al. Treatment of polyarteritis nodosa related to hepatitis B virus with short term steroid therapy associated with antiviral agents and plasma exchanges. A prospective trial in 33 patients. J Rheumatol. Feb. 1993;20(2):289-98. Not relevant outcomes. [pmid: 8097249].
154 Guillevin L, Lhote F, Sauvaget F, Deblois P, Rossi F, Levallois D, et al. Treatment of polyarteritis nodosa related to hepatitis B virus with interferon-alpha and plasma exchanges. Ann Rheum Dis. May. 1994;53(5):334-7. Not relevant outcomes. [pmid: 7912504].
155 Guillevin L, Mahr A, Cohen P, Larroche C, Queyrel V, Loustaud-Ratti V, et al. Short-term corticosteroids then lamivudine and plasma exchanges to treat hepatitis B virus-related polyarteritis nodosa. Arthritis Rheum. Jun 15. 2004;51(3):482-7. Not eligible target population. [pmid: 15188337].
156 Guillevin L, Pagnoux C, Guillevin L, Pagnoux C. Therapeutic strategies for systemic necrotizing vasculitides. Allergol. Jun. 2007;56(2):105-11. Not eligible exposure.
157 Gunther M, Neuhaus R, Bauer T, Jilg W, Holtz JA, Bienzle U, et al. Immunization with an adjuvant hepatitis B vaccine in liver transplant recipients: antibody decline and booster vaccination with conventional vaccine. Liver Transpl. Feb. 2006;12(2):316-9. Not eligible target population. [pmid: 16447191].
158 Gunther S, Baginski S, Kissel H, Reinke P, Kruger DH, Will H, et al. Accumulation and persistence of hepatitis B virus core gene deletion mutants in renal transplant patients are associated with end-stage liver disease. Hepatology. Oct. 1996;24(4):751-8. Not eligible target population. [pmid: 8855172].
159 Hadem J, Stiefel P, Bahr MJ, Tillmann HL, Rifai K, Klempnauer J, et al. Prognostic implications of lactate, bilirubin, and etiology in German patients with acute liver failure. Clinical Gastroenterology & Hepatology. Mar. 2008;6(3):339-45. Not eligible target population. [pmid: 18328438].
160 Hadengue A, N'Dri N, Benhamou JP. Relative risk of hepatocellular carcinoma in HBsAg positive vs alcoholic cirrhosis. A cross-sectional study. Liver. Jun. 1990;10(3):147-51. Not relevant outcomes. [pmid: 2166890].
161 Hadler SC, Alcala de Monzon M, Rivero D, Perez M, Bracho A, Fields H, et al. Epidemiology and long-term consequences of hepatitis delta virus infection in the Yucpa Indians of Venezuela. Am J Epidemiol. Dec 15. 1992;136(12):1507-16. Not eligible target population. [pmid: 1288280].
162 Hadziyannis SJ, Tassopoulos NC, Heathcote EJ, Chang TT, Kitis G, Rizzetto M, et al. Long-term therapy with adefovir dipivoxil for HBeAg-negative chronic hepatitis B. N Engl J Med. Jun 30. 2005;352(26):2673-81. Not relevant outcomes. [pmid: 15987916].
163 Han KH, Ahn SH, Han KH, Ahn SH. How to predict HCC development in patients with chronic B viral liver disease?. Intervirology. Jan–Feb. 2005;48(1):23-8. Not relevant outcomes. [pmid: 15785086].
164 Hann HW, Fontana RJ, Wright T, Everson G, Baker A, Schiff ER, et al. A United States compassionate use study of lamivudine treatment in nontransplantation candidates with decompensated hepatitis B virus-related cirrhosis. Liver Transpl. Jan. 2003;9(1):49-56. Not relevant outcomes. [pmid: 12514773].
165 Hann HW, Lee J, Bussard A, Liu C, Jin YR, Guha K, et al. Preneoplastic markers of hepatitis B virus-associated hepatocellular carcinoma. Cancer Res. Oct 15. 2004;64(20):7329-35. Not relevant outcomes. [pmid: 15492253].
166 Harris RA, Chen G, Lin WY, Shen FM, London WT, Evans AA, et al. Spontaneous clearance of high-titer serum HBV DNA and risk of hepatocellular carcinoma in a Chinese population. Cancer Causes Control. Dec. 2003;14(10):995-1000. Less than 1000 patients and not US study. [pmid: 14750539].
167 Hasegawa I, Orito E, Tanaka Y, Hirashima N, Sakakibara K, Sakurai M, et al. Impact of occult hepatitis B virus infection on efficacy and prognosis of interferon-alpha therapy for patients with chronic hepatitis C. Liver International. Apr. 2005;25(2):247-53. Not eligible exposure. [pmid: 15780046].
168 Hassan MM, Zaghloul AS, El-Serag HB, Soliman O, Patt YZ, Chappell CL, et al. The role of hepatitis C in hepatocellular carcinoma: a case control study among Egyptian patients. J Clin Gastroenterol. Aug. 2001;33(2):123-6. Not eligible target population. [pmid: 11468438].
169 Heintges T, Mohr L, Hensel F, Petry W, Borchard F, Haussinger D, et al. Value of liver biopsy prior to interferon therapy for chronic viral hepatitis. Dig Dis Sci. Jul. 1998;43(7):1562-5. Not relevant outcomes. [pmid: 9690395].
170 Helvaci M, Ozkaya B, Ozbal E, Ozinel S, Yaprak I, Helvaci M, et al. Efficacy of interferon therapy on serum fibronectin levels in children with chronic hepatitis B infection. Pediatr Int. Jun. 1999;41(3):270-3. Not eligible target population. [pmid: 10365576].
171 Hemming AW, Cattral MS, Greig PD, Philosophe B, Superina RA, Lilly LB, et al. The University of Toronto liver transplant program. Clin Transpl 1996:177–85. Not relevant outcomes
172 Hemsell DL, Hemsell DL. HIV and blood-borne diseases in relation to gynecologic surgery. Curr Opin Obstet Gynecol. Jun. 1993;5(3):340-5. Review. [pmid: 8329650].
173 Hessol NA, Koblin BA, van Griensven GJ, Bacchetti P, Liu JY, Stevens CE, et al. Progression of human immunodeficiency virus type 1 (HIV-1) infection among homosexual men in hepatitis B vaccine trial cohorts in Amsterdam, New York City, and San Francisco, 1978-1991. Am J Epidemiol. Jun 1. 1994;139(11):1077-87. Not eligible exposure. [pmid: 8192140].
174 Hilleman MR, Hilleman MR. Newer directions in vaccine development and utilization. J Infect Dis. Mar. 1985;151(3):407-19. Review. [pmid: 2982958].
175 Hoffmann G, Berglund G, Elmstahl S, Eriksson S, Verbaan H, Widell A, et al. Prevalence and clinical spectrum of chronic viral hepatitis in a middle-aged Swedish general urban population. Scand J Gastroenterol. Aug. 2000;35(8):861-5. Not relevant outcomes. [pmid: 10994626].
176 Hollands MJ, Huang JF, Adams W, Little JM, Hollands MJ, Huang JF, et al. Hepatocellular carcinoma in western Sydney. Ann Acad Med Singapore. Jan. 1988;17(1):89-95. Not eligible exposure. [pmid: 2461143].
177 Hosenpud JD, Pamidi SR, Fiol BS, Cinquegrani MP, Keck BM, Hosenpud JD, et al. Outcomes in patients who are hepatitis B surface antigen-positive before transplantation: an analysis and study using the joint ISHLT/UNOS thoracic registry. J Heart Lung Transplant. Aug. 2000;19(8):781-5. Not eligible target population. [pmid: 10967272].
178 Hsiao TJ, Liao HW, Hsieh PS, Wong RH, Hsiao TJ, Liao HWC, et al. Risk of betel quid chewing on the development of liver cirrhosis: a community-based case-control study. Ann Epidemiol. Jun. 2007;17(6):479-85. Not eligible target population. [pmid: 17448681].
179 Hu KQ, Hu KQ. Occult hepatitis B virus infection and its clinical implications. Journal of Viral Hepatitis. Jul. 2002;9(4):243-57. Review. [pmid: 12081601].
180 Huang CC, Lai MK, Fong MT, Huang CC, Lai MK, Fong MT. Hepatitis B liver disease in cyclosporine-treated renal allograft recipients. Transplantation. Mar. 1990;49(3):540-4. Not eligible target population. [pmid: 2316016].
181 Huang Y, Wang Z, An S, Zhou B, Zhou Y, Chan HL, et al. Role of hepatitis B virus genotypes and quantitative HBV DNA in metastasis and recurrence of hepatocellular carcinoma. Journal of Medical Virology. Apr. 2008;80(4):591-7. Less than 1000 patients and not US study. [pmid: 18297705].
182 Huang YH, Wu JC, Chen CH, Chang TT, Lee PC, Chau GY, et al. Comparison of recurrence after hepatic resection in patients with hepatitis B vs. hepatitis C-related small hepatocellular carcinoma in hepatitis B virus endemic area. Liver International. Apr. 2005;25(2):236-41. Not relevant outcomes. [pmid: 15780044].
183 Hui AY, Chan HL, Leung NW, Hung LC, Chan FK, Sung JJ, et al. Survival and prognostic indicators in patients with hepatitis B virus-related cirrhosis after onset of hepatic decompensation. J Clin Gastroenterol. May–Jun. 2002;34(5):569-72. Less than 1000 patients and not US study. [pmid: 11960072].
184 Hui AY, Chan HL, Wong VW, Liew CT, Chim AM, Chan FK, et al. Identification of chronic hepatitis B patients without significant liver fibrosis by a simple noninvasive predictive model. American Journal of Gastroenterology. Mar. 2005;100(3):616-23. Not relevant outcomes. [pmid: 15743360].
185 Hui CK, Lie A, Au WY, Leung YH, Ma SY, Cheung WW, et al. A long-term follow-up study on hepatitis B surface antigen-positive patients undergoing allogeneic hematopoietic stem cell transplantation. Blood. Jul 15. 2005;106(2):464-9. Not relevant outcomes. [pmid: 15797991].
186 Hui CK, Zhang HY, Lee NP, Chan W, Yueng YH, Leung KW, et al. Serum adiponectin is increased in advancing liver fibrosis and declines with reduction in fibrosis in chronic hepatitis B. Journal of Hepatology. Aug. 2007;47(2):191-202. Not relevant outcomes. [pmid: 17462782].
187 Huo T, Wu JC, Hwang SJ, Lai CR, Lee PC, Tsay SH, et al. Factors predictive of liver cirrhosis in patients with chronic hepatitis B: a multivariate analysis in a longitudinal study. Eur J Gastroenterol Hepatol. Jun. 2000;12(6):687-93. Less than 1000 patients and not US study. [pmid: 10912490].
188 Huo TI, Wu JC, Hsia CY, Chau GY, Lui WY, Huang YH, et al. Hepatitis C virus infection is a risk factor for tumor recurrence after resection of small hepatocellular carcinomas. World Journal of Surgery. Aug. 2004;28(8):787-91. Less than 1000 patients and not US study. [pmid: 15457359].
189 Huo TI, Wu JC, Lee PC, Tsay SH, Chang FY, Lee SD, et al. Diabetes mellitus as a risk factor of liver cirrhosis in patients with chronic hepatitis B virus infection. J Clin Gastroenterol. Apr. 2000;30(3):250-4. Less than 1000 patients and not US study. [pmid: 10777182].
190 Hwang SJ, Wu JC, Lee CN, Yen FS, Lu CL, Lin TP, et al. A prospective clinical study of isoniazid-rifampicin-pyrazinamide-induced liver injury in an area endemic for hepatitis B. Journal of Gastroenterology & Hepatology. Jan. 1997;12(1):87-91. Not eligible target population. [pmid: 9076631].
191 Iida F, Iida R, Kamijo H, Takaso K, Miyazaki Y, Funabashi W, et al. Chronic Japanese schistosomiasis and hepatocellular carcinoma: ten years of follow-up in Yamanashi Prefecture, Japan. Bull World Health Organ. 1999;77(7):573-81. Not eligible exposure. [pmid: 10444881].
192 Iijima T, Nambu M, Iijima T, Nambu M. Significance of hepatitis B surface antigen carriers in a cohort. Trop Gastroenterol. Oct–Dec. 1988;9(4):196-8. Less than 1000 patients and not US study. [pmid: 2851885].
193 Ikeda K, Arase Y, Kobayashi M, Saitoh S, Someya T, Hosaka T, et al. Significance of multicentric cancer recurrence after potentially curative ablation of hepatocellular carcinoma: a longterm cohort study of 892 patients with viral cirrhosis. J Gastroenterol. 2003;38(9):865-76. Less than 1000 patients and not US study. [pmid: 14569444].
194 Ikeda K, Arase Y, Kobayashi M, Someya T, Hosaka T, Saitoh S, et al. Hepatitis B virus-related hepatocellular carcinogenesis and its prevention. Intervirology. Jan–Feb. 2005;48(1):29-38. Less than 1000 patients and not US study. [pmid: 15785087].
195 Ikeda K, Arase Y, Saitoh S, Kobayashi M, Someya T, Hosaka T, et al. Long-term outcome of HBV carriers with negative HBe antigen and normal aminotransferase. Am J Med. Nov. 2006;119(11):977-85. Less than 1000 patients and not US study. [pmid: 17071167].
196 Ikeda K, Saitoh S, Koida I, Arase Y, Tsubota A, Chayama K, et al. A multivariate analysis of risk factors for hepatocellular carcinogenesis: a prospective observation of 795 patients with viral and alcoholic cirrhosis. Hepatology. Jul. 1993;18(1):47-53. Less than 1000 patients and not US study. [pmid: 7686879].
197 Ikoma J, Kaito M, Ishihara T, Nakagawa N, Kamei A, Fujita N, et al. Early diagnosis of hepatocellular carcinoma using a sensitive assay for serum des-gamma-carboxy prothrombin: a prospective study. Hepato-Gastroenterology. Jan–Feb. 2002;49(43):235-8. Not eligible exposure. [pmid: 11941963].
198 Imazeki F, Yokosuka O, Fukai K, Hiraide A, Saisho H, Imazeki F, et al. Significance of prior hepatitis B virus infection in the development of hepatocellular carcinoma in patients with chronic hepatitis C. Dig Dis Sci. Sep. 2003;48(9):1786-92. Not eligible exposure. [pmid: 14561002].
199 Ingsathit A, Thakkinstian A, Kantachuvesiri S, Sumethkul V, Ingsathit A, Thakkinstian A, et al. Different impacts of hepatitis B virus and hepatitis C virus on the outcome of kidney transplantation. Transplant Proc. Jun. 2007;39(5):1424-8. Not eligible target population. [pmid: 17580153].
200 Ioannou GN, Splan MF, Weiss NS, McDonald GB, Beretta L, Lee SP. Incidence and predictors of hepatocellular carcinoma in patients with cirrhosis. Clinical Gastroenterology & Hepatology. Aug. 2007;5(8):938-45. Not eligible target population. [pmid: 17509946].
201 Ishii M, Gama H, Chida N, Ueno Y, Shinzawa H, Takagi T, et al. Simultaneous measurements of serum alpha-fetoprotein and protein induced by vitamin K absence for detecting hepatocellular carcinoma. South Tohoku District Study Group. American Journal of Gastroenterology. Apr. 2000;95(4):1036-40. Not eligible exposure. [pmid: 10763956].
202 Iwao T, Toyonaga A, Oho K, Sakai T, Tayama C, Masumoto H, et al. Portal-hypertensive gastropathy develops less in patients with cirrhosis and fundal varices. Journal of Hepatology. Jun. 1997;26(6):1235-41. Not eligible exposure. [pmid: 9210609].
203 Iwao T, Toyonaga A, Oho K, Tayama C, Masumoto H, Sakai T, et al. Value of Doppler ultrasound parameters of portal vein and hepatic artery in the diagnosis of cirrhosis and portal hypertension. American Journal of Gastroenterology. Jun. 1997;92(6):1012-7. Not eligible exposure. [pmid: 9177521].
204 Izzo F, Cremona F, Delrio P, Leonardi E, Castello G, Pignata S, et al. Soluble interleukin-2 receptor levels in hepatocellular cancer: a more sensitive marker than alfa fetoprotein. Ann Surg Oncol. Mar. 1999;6(2):178-85. Not eligible exposure. [pmid: 10082044].
205 Izzo F, Cremona F, Ruffolo F, Palaia R, Parisi V, Curley S, et al. Detection of hepatocellular cancer during screening of 1125 patients with chronic hepatitis virus infection. J Chemother. Apr. 1997;9(2):151-2. Not relevant outcomes. [pmid: 9176768].
206 Izzo F, Cremona F, Ruffolo F, Palaia R, Parisi V, Curley SA, et al. Outcome of 67 patients with hepatocellular cancer detected during screening of 1125 patients with chronic hepatitis. Ann Surg. Apr. 1998;227(4):513-8. Less than 1000 patients and not US study. [pmid: 9563539].
207 Jacobs RJ, Meyerhoff AS, Jacobs RJ, Meyerhoff AS. Cost-effectiveness of hepatitis A/B vaccine versus hepatitis B vaccine in public sexually transmitted disease clinics. Sex Transm Dis. Nov. 2003;30(11):859-65. Not eligible exposure. [pmid: 14603096].
208 Jadoul M, Goubau P, Jadoul M, Goubau P. Is anti-hepatitis B virus (HBV) immunization successful in elderly hemodialysis (HD) patients?. Clin Nephrol. Oct. 2002;58(4):301-4. Not eligible exposure. [pmid: 12400846].
209 Jang JW, Choi JY, Bae SH, Yoon SK, Woo HY, Chang UI, et al. The impact of hepatitis B viral load on recurrence after complete necrosis in patients with hepatocellular carcinoma who receive transarterial chemolipiodolization: implications for viral suppression to reduce the risk of cancer recurrence. Cancer. Oct 15. 2007;110(8):1760-7. Not eligible target population. [pmid: 17724708].
210 Jang JW, Lee YC, Kim MS, Lee SY, Bae SH, Choi JY, et al. A 13-year longitudinal study of the impact of double mutations in the core promoter region of hepatitis B virus on HBeAg seroconversion and disease progression in patients with genotype C chronic active hepatitis. Journal of Viral Hepatitis. Mar. 2007;14(3):169-75. Less than 1000 patients and not US study. [pmid: 17305882].
211 Jeng JE, Tsai JF, Chuang LY, Ho MS, Lin ZY, Hsieh MY, et al. Heat shock protein A1B 1267 polymorphism is highly associated with risk and prognosis of hepatocellular carcinoma: a case-control study. Medicine. Mar. 2008;87(2):87-98. Not eligible exposure. [pmid: 18344806].
212 Jung YJ, Kim YJ, Kim LH, Lee SO, Park BL, Shin HD, et al. Putative association of Fas and FasL gene polymorphisms with clinical outcomes of hepatitis B virus infection. Intervirology. 2007;50(5):369-76. Not eligible exposure. [pmid: 17938571].
213 Kaczynski J, Hansson G, Hermodsson S, Olsson R, Wallerstedt S, Kaczynski J, et al. Minor role of hepatitis B and C virus infection in the etiology of hepatocellular carcinoma in a low-endemic area. Scand J Gastroenterol. Aug. 1996;31(8):809-13. Not eligible target population. [pmid: 8858752].
214 Kallinowski B, Benz C, Buchholz L, Stremmel W, Kallinowski B, Benz C, et al. Accelerated schedule of hepatitis B vaccination in liver transplant candidates. Transplant Proc. May. 1998;30(3):797-9. Not eligible exposure. [pmid: 9595103].
215 Kamihira S, Momita S, Ikeda S, Yamada Y, Sohda H, Atogami S, et al. Cohort study of hepatotropic virus and human T lymphotropic virus type-I infections in an area endemic for adult T cell leukemia. Jpn J Med. Nov–Dec. 1991;30(6):492-7. Not relevant outcomes. [pmid: 1665877].
216 Kanematsu M, Semelka RC, Matsuo M, Kondo H, Enya M, Goshima S, et al. Gadolinium-enhanced MR imaging of the liver: optimizing imaging delay for hepatic arterial and portal venous phases—a prospective randomized study in patients with chronic liver damage. Radiology. Nov. 2002;225(2):407-15. Not eligible exposure. [pmid: 12409573].
217 Kao JH, Chen PJ, Lai MY, Chen DS, Kao JH, Chen PJ, et al. Hepatitis B genotypes correlate with clinical outcomes in patients with chronic hepatitis B. Gastroenterology. Mar. 2000;118(3):554-9. Not relevant outcomes. [pmid: 10702206].
218 Kao JH, Chen PJ, Lai MY, Chen DS, Kao JH, Chen PJ, et al. Basal core promoter mutations of hepatitis B virus increase the risk of hepatocellular carcinoma in hepatitis B carriers. Gastroenterology. Feb. 2003;124(2):327-34. Less than 1000 patients and not US study. [pmid: 12557138].
219 Kapoor D, Guptan RC, Wakil SM, Kazim SN, Kaul R, Agarwal SR, et al. Beneficial effects of lamivudine in hepatitis B virus-related decompensated cirrhosis. Journal of Hepatology. Aug. 2000;33(2):308-12. Not eligible target population. [pmid: 10952249].
220 Kato I, Tominaga S, Ikari A, Kato I, Tominaga S, Ikari A. The risk and predictive factors for developing liver cancer among patients with decompensated liver cirrhosis. Jpn J Clin Oncol. Aug. 1992;22(4):278-85. Not eligible exposure. [pmid: 1279245].
221 Katz LH, Fraser A, Gafter-Gvili A, Leibovici L, Tur-Kaspa R. Lamivudine prevents reactivation of hepatitis B and reduces mortality in immunosuppressed patients: systematic review and meta-analysis. Journal of Viral Hepatitis. Feb. 2008;15(2):89-102. Not eligible target population. [pmid: 18184191].
222 Keeffe EB, Keeffe EB. Acute hepatitis A and B in patients with chronic liver disease: prevention through vaccination. Am J Med. Oct. 2005;118(Suppl 10A):21S-7S. Review.
223 Keeffe EB, Marcellin P, Keeffe EB, Marcellin P. New and emerging treatment of chronic hepatitis B. Clinical Gastroenterology & Hepatology. Mar. 2007;5(3):285-94. Review. [pmid: 17218162].
224 Kew MC, Kew MC. Hepatitis C virus and hepatocellular carcinoma. FEMS Microbiol Rev. Jul. 1994;14(3):211-9. Review. [pmid: 8086196].
225 Kew MC, Kew MC. Synergistic interaction between aflatoxin B1 and hepatitis B virus in hepatocarcinogenesis. Liver International. Dec. 2003;23(6):405-9. Review. [pmid: 14986813].
226 Khan M, Haq SA, Ahmed N, Matin MA, Khan M, Haq SA, et al. Etiology and clinical profile of hepatocellular carcinoma in Bangladesh. Bangladesh Med Res Counc Bull. Apr. 1997;23(1):16-24. Not relevant outcomes. [pmid: 9363673].
227 Kim KH, Lee HR, Min CH, Jeong H, Hong SH, Lee YS, et al. Prevalence of antibodies to hepatitis C virus in patients with various types of liver diseases. Korean J Intern Med. Jan. 1992;7(1):9-12. Not eligible exposure. [pmid: 1282365].
228 Kim KM, Choi WB, Lim YS, Lee HC, Chung YH, Lee YS, et al. Adefovir dipivoxil alone or in combination with ongoing lamivudine in patients with decompensated liver disease and lamivudine-resistant hepatitis B virus. J Korean Med Sci. Oct. 2005;20(5):821-8. Not relevant outcomes. [pmid: 16224157].
229 Kim YJ, Kim BG, Jung JO, Yoon JH, Lee HS, Kim YJ, et al. High rates of progressive hepatic functional deterioration whether lamivudine therapy is continued or discontinued after emergence of a lamivudine-resistant mutant: a prospective randomized controlled study. J Gastroenterol. Mar. 2006;41(3):240-9. Not eligible target population. [pmid: 16699858].
230 Kim YJ, Yoon JH, Kim CY, Kim LH, Park BL, Shin HD, et al. IGF2 polymorphisms are associated with hepatitis B virus clearance and hepatocellular carcinoma. Biochem Biophys Res Commun. Jul 21. 2006;346(1):38-44. Not relevant outcomes. [pmid: 16750516].
231 Kirk AP, Dooley JS, Hunt RH, Kirk AP, Dooley JS, Hunt RH. Peptic ulceration in patients with chronic liver disease. Dig Dis Sci. Oct. 1980;25(10):756-60. Not eligible exposure. [pmid: 7428583].
232 Kirk GD, Camus-Randon AM, Mendy M, Goedert JJ, Merle P, Trepo C, et al. Ser-249 p53 mutations in plasma DNA of patients with hepatocellular carcinoma from The Gambia. J Natl Cancer Inst. Jan 19. 2000;92(2):148-53. Not eligible target population. [pmid: 10639517].
233 Kirk GD, Lesi OA, Mendy M, Akano AO, Sam O, Goedert JJ, et al. The Gambia Liver Cancer Study: Infection with hepatitis B and C and the risk of hepatocellular carcinoma in West Africa. Hepatology. Jan. 2004;39(1):211-9. Not relevant outcomes. [pmid: 14752840].
234 Kleinman S, Marshall D, AuBuchon J, Patton M, Kleinman S, Marshall D, et al. Survival after transfusion as assessed in a large multistate US cohort. Transfusion. Mar. 2004;44(3):386-90. Not eligible exposure. [pmid: 14996196].
235 Kletzmayr J, Watschinger B, Muller C, Demetriou D, Puchhammer-Stockl E, Ferenci P, et al. Twelve months of lamivudine treatment for chronic hepatitis B virus infection in renal transplant recipients. Transplantation. Nov 15. 2000;70(9):1404-7. Not eligible target population. [pmid: 11087161].
236 Knoll A, Hartmann A, Hamoshi H, Weislmaier K, Jilg W, Knoll A, et al. Serological pattern “anti-HBc alone”: characterization of 552 individuals and clinical significance. World J Gastroenterol. Feb 28. 2006;12(8):1255-60. Less than 1000 patients and not US study. [pmid: 16534880].
237 Ko C, Siddaiah N, Berger J, Gish R, Brandhagen D, Sterling RK, et al. Prevalence of hepatic iron overload and association with hepatocellular cancer in end-stage liver disease: results from the National Hemochromatosis Transplant Registry. Liver International. Dec. 2007;27(10):1394-401. Not eligible exposure. [pmid: 17927713].
238 Komori M, Yuki N, Nagaoka T, Yamashiro M, Mochizuki K, Kaneko A, et al. Long-term clinical impact of occult hepatitis B virus infection in chronic hepatitis B patients. Journal of Hepatology. Dec. 2001;35(6):798-804. Not relevant outcomes. [pmid: 11738108].
239 Kondili LA, Osman H, Mutimer D, Kondili LA, Osman H, Mutimer D. The use of lamivudine for patients with acute hepatitis B (a series of cases). Journal of Viral Hepatitis. Sep. 2004;11(5):427-31. Not eligible target population. [pmid: 15357647].
240 Kong CW, Lay CS, Tsai YT, Lee SD, Lai KH, Lo KJ, et al. Hemodynamic effect of propranolol on portal hypertension in patients with HBsAg-positive cirrhosis. Dig Dis Sci. Dec. 1986;31(12):1303-6. Not relevant outcomes. [pmid: 3803132].
241 Kuang SY, Jackson PE, Wang JB, Lu PX, Munoz A, Qian GS, et al. Specific mutations of hepatitis B virus in plasma predict liver cancer development. Proc Natl Acad Sci U S A. Mar 9. 2004;101(10):3575-80. Less than 1000 patients and not US study. [pmid: 14990795].
242 Kubo S, Tanaka H, Shuto T, Takemura S, Yamamoto T, Kanazawa A, et al. Clinicopathologic features and outcome after liver resection for hepatocellular carcinoma in patients with concurrent versus previous chronic hepatitis B. Surg. 2005;35(3):216-22. Not eligible target population.
243 Kurbanov F, Tanaka Y, Elkady A, Oyunsuren T, Mizokami M. Tracing hepatitis C and Delta viruses to estimate their contribution in HCC rates in Mongolia. Journal of Viral Hepatitis. Sep. 2007;14(9):667-74. Not eligible exposure. [pmid: 17697020].
244 Kwon CH, Suh KS, Yi NJ, Chang SH, Cho YB, Cho JY, et al. Long-term protection against hepatitis B in pediatric liver recipients can be achieved effectively with vaccination after transplantation. Pediatr Transplant. Jun. 2006;10(4):479-86. Not eligible target population. [pmid: 16712607].
245 Lacombe K, Boyd A, Desvarieux M, Serfaty L, Bonnord P, Gozlan J, et al. Impact of chronic hepatitis C and/or D on liver fibrosis severity in patients co-infected with HIV and hepatitis B virus. AIDS. Nov 30. 2007;21(18):2546-9. Not eligible exposure. [pmid: 18025897].
246 Lacombe K, Massari V, Girard PM, Serfaty L, Gozlan J, Pialoux G, et al. Major role of hepatitis B genotypes in liver fibrosis during coinfection with HIV. AIDS. Feb 14. 2006;20(3):419-27. Not relevant outcomes. [pmid: 16439876].
247 Lai M, Hyatt BJ, Nasser I, Curry M, Afdhal NH. The clinical significance of persistently normal ALT in chronic hepatitis B infection. Journal of Hepatology. Dec. 2007;47(6):760-7. Not relevant outcomes. [pmid: 17928090].
248 Lam KC, Lai CL, Trepo C, Wu PC, Lam KC, Lai CL, et al. Deleterious effect of prednisolone in HBsAg-positive chronic active hepatitis. N Engl J Med. Feb 12. 1981;304(7):380-6. Not eligible target population. [pmid: 7005678].
249 Lam KC, Lai CL, Wu PC, Todd D, Lam KC, Lai CL, et al. Etiological spectrum of liver cirrhosis in the Chinese. J Chronic Dis. 1980;33(6):375-81. Not eligible exposure. [pmid: 7372773].
250 Lampertico P, Del Ninno E, Vigano M, Romeo R, Donato MF, Sablon E, et al. Long-term suppression of hepatitis B e antigen-negative chronic hepatitis B by 24-month interferon therapy. Hepatology. Apr. 2003;37(4):756-63. Less than 1000 patients and not US study. [pmid: 12668967].
251 Lampertico P, Vigano M, Manenti E, Iavarone M, Sablon E, Colombo M. Low resistance to adefovir combined with lamivudine: a 3-year study of 145 lamivudine-resistant hepatitis B patients. Gastroenterology. Nov. 2007;133(5):1445-51. Not relevant outcomes. [pmid: 17983801].
252 Lanjewar DN, Rao RJ, Kulkarni SB, Hira SK, Lanjewar DN, Rao RJ, et al. Hepatic pathology in AIDS: a pathological study from Mumbai, India. HIV Medicine. Jul. 2004;5(4):253-7. Not eligible exposure. [pmid: 15236613].
253 Lascar RM, Lopes AR, Gilson RJ, Dunn C, Johnstone R, Copas A, et al. Effect of HIV infection and antiretroviral therapy on hepatitis B virus (HBV)-specific T cell responses in patients who have resolved HBV infection. J Infect Dis. Apr 1. 2005;191(7):1169-79. Not relevant outcomes. [pmid: 15747254].
254 Laskus T, Radkowski M, Nowicki M, Wang LF, Vargas H, Rakela J, et al. Association between hepatitis B virus core promoter rearrangements and hepatocellular carcinoma. Biochem Biophys Res Commun. Mar 27. 1998;244(3):812-4. Not eligible target population. [pmid: 9535748].
255 Lausten SB, Ibrahim TM, El-Sefi T, Jensen LS, Gesser B, Larsen CG, et al. Systemic and cell-mediated immune response after laparoscopic and open cholecystectomy in patients with chronic liver disease. A randomized, prospective study. Dig Surg. 1999;16(6):471-7. Not eligible exposure. [pmid: 10805546].
256 Lebensztejn DM, Sobaniec-Lotowska ME, Bauer M, Kaczmarski M, Voelker M, Schuppan D, et al. Serum fibrosis markers as predictors of an antifibrotic effect of interferon alfa in children with chronic hepatitis B. Eur J Gastroenterol Hepatol. Aug. 2005;17(8):843-8. Not eligible target population. [pmid: 16003134].
257 Lee HS, Kim KM, Yoon JH, Lee TR, Suh KS, Lee KU, et al. Therapeutic efficacy of transcatheter arterial chemoembolization as compared with hepatic resection in hepatocellular carcinoma patients with compensated liver function in a hepatitis B virus-endemic area: a prospective cohort study. J Clin Oncol. Nov 15. 2002;20(22):4459-65. Not eligible target population. [pmid: 12431969].
258 Lee SM, Wong NW, Lee SM, Wong NW. Survival in hepatitis-B cirrhosis compared to alcoholic cirrhosis in patients with Child's C liver disease: a prospective study of endoscopic sclerotherapy for bleeding oesophageal varices. Singapore Med J. Feb. 1994;35(1):53-6. Less than 1000 patients and not US study. [pmid: 8009280].
259 Lehmann FG, Wegener T, Lehmann FG, Wegener T. Etiology of human liver cancer: controlled prospective study in liver cirrhosis. J Toxicol Environ Health. Mar–May. 1979;5(23):281-99. Not eligible exposure. [pmid: 89198].
260 Leung TW, Tang AM, Zee B, Lau WY, Lai PB, Leung KL, et al. Construction of the Chinese University Prognostic Index for hepatocellular carcinoma and comparison with the TNM staging system, the Okuda staging system, and the Cancer of the Liver Italian Program staging system: a study based on 926 patients. Cancer. Mar 15. 2002;94(6):1760-9. Not eligible target population. [pmid: 11920539].
261 Levy G, Burra P, Cavallari A, Duvoux C, Lake J, Mayer AD, et al. Improved clinical outcomes for liver transplant recipients using cyclosporine monitoring based on 2-hr post-dose levels (C2). Transplantation. Mar 27. 2002;73(6):953-9. Not eligible exposure. [pmid: 11923699].
262 Levy MT, Chen JJ, McGuinness PH, Koorey D, Sheil AG, McCaughan GW, et al. Liver transplantation for hepatitis C-associated cirrhosis in a single Australian centre: referral patterns and transplant outcomes. Journal of Gastroenterology & Hepatology. Jun. 1997;12(6):453-9. Not eligible exposure. [pmid: 9195404].
263 Liang R, Lau GK, Kwong YL, Liang R, Lau GK, Kwong YL. Chemotherapy and bone marrow transplantation for cancer patients who are also chronic hepatitis B carriers: a review of the problem. J Clin Oncol. Jan. 1999;17(1):394-8. Review. [pmid: 10458258].
264 Liang TJ, Jeffers LJ, Reddy KR, De Medina M, Parker IT, Cheinquer H, et al. Viral pathogenesis of hepatocellular carcinoma in the United States. Hepatology. Dec. 1993;18(6):1326-33. Not eligible target population. [pmid: 8244256].
265 Liaw YF, Chen JJ, Chen TJ, Liaw YF, Chen JJ, Chen TJ. Acute exacerbation in patients with liver cirrhosis: a clinicopathological study. Liver. Jun. 1990;10(3):177-84. Not eligible target population. [pmid: 1696678].
266 Liaw YF, Chen YC, Sheen IS, Chien RN, Yeh CT, Chu CM, et al. Impact of acute hepatitis C virus superinfection in patients with chronic hepatitis B virus infection. Gastroenterology. Apr. 2004;126(4):1024-9. Not eligible target population. [pmid: 15057742].
267 Liaw YF, Liaw YF. Hepatitis B virus replication and liver disease progression: the impact of antiviral therapy. Antiviral Therapy. 2006;11(6):669-79. Review. [pmid: 17310811].
268 Liaw YF, Lin DY, Chen TJ, Chu CM, Liaw YF, Lin DY, et al. Natural course after the development of cirrhosis in patients with chronic type B hepatitis: a prospective study. Liver. Aug. 1989;9(4):235-41. Less than 1000 patients and not US study. [pmid: 2770436].
269 Liaw YF, Sheen IS, Chen TJ, Chu CM, Pao CC, Liaw YF, et al. Incidence, determinants and significance of delayed clearance of serum HBsAg in chronic hepatitis B virus infection: a prospective study. Hepatology. Apr. 1991;13(4):627-31. Not relevant outcomes. [pmid: 2010157].
270 Liaw YF, Sung JJ, Chow WC, Farrell G, Lee CZ, Yuen H, et al. Lamivudine for patients with chronic hepatitis B and advanced liver disease. N Engl J Med. Oct 7. 2004;351(15):1521-31. Less than 1000 patients and not US study. [pmid: 15470215].
271 Liaw YF, Tai DI, Chen TJ, Chu CM, Huang MJ, Liaw YF, et al. Alpha-fetoprotein changes in the course of chronic hepatitis: relation to bridging hepatic necrosis and hepatocellular carcinoma. Liver. Jun. 1986;6(3):133-7. Less than 1000 patients and not US study. [pmid: 2427909].
272 Liaw YF, Tai DI, Chu CM, Chen TJ, Liaw YF, Tai DI, et al. The development of cirrhosis in patients with chronic type B hepatitis: a prospective study. Hepatology. May–Jun. 1988;8(3):493-6. Less than 1000 patients and not US study. [pmid: 3371868].
273 Liaw YF, Tai DI, Chu CM, Lin DY, Sheen IS, Chen TJ, et al. Early detection of hepatocellular carcinoma in patients with chronic type B hepatitis. A prospective study. Gastroenterology. Feb. 1986;90(2):263-7. Less than 1000 patients and not US study. [pmid: 2416625].
274 Lieberman HM, Shafritz D, Lieberman HM, Shafritz D. Persistent hepatitis B virus infection and hepatocellular carcinoma. Prog Liver Dis. 1986;8:395-415. Review. [pmid: 3012640].
275 Liew PL, Lee WJ, Lee YC, Wang HH, Wang W, Lin YC, et al. Hepatic histopathology of morbid obesity: concurrence of other forms of chronic liver disease. Obes Surg. Dec. 2006;16(12):1584-93. Not eligible exposure. [pmid: 17217634].
276 Lill JS, O'Sullivan T, Bauer LA, Horn JR, Carithers R Jr, Strandness DE, et al. Pharmacokinetics of diclofenac sodium in chronic active hepatitis and alcoholic cirrhosis. J Clin Pharmacol. Mar. 2000;40(3):250-7. Not relevant outcomes. [pmid: 10709153].
277 Lim LL, Wai CT, Lee YM, Kong HL, Lim R, Koay E, et al. Prophylactic lamivudine prevents hepatitis B reactivation in chemotherapy patients. Alimentary Pharmacology & Therapeutics. Nov. 2002;16(11):1939-44. Not eligible target population. [pmid: 12390103].
278 Lin DY, Sheen IS, Chiu CT, Lin SM, Kuo YC, Liaw YF, et al. Ultrasonographic changes of early liver cirrhosis in chronic hepatitis B: a longitudinal study. J Clin Ultrasound. Jun. 1993;21(5):303-8. Not relevant outcomes. [pmid: 8514896].
279 Lin DY, Sheen IS, Chu CM, Liaw YF, Lin DY, Sheen IS, et al. A prospective randomized trial of colchicine in prevention of liver cirrhosis in chronic hepatitis B patients. Alimentary Pharmacology & Therapeutics. Dec. 1996;10(6):961-6. Less than 1000 patients and not US study. [pmid: 8971295].
280 Lin SM, Sheen IS, Chien RN, Chu CM, Liaw YF, Lin SM, et al. Long-term beneficial effect of interferon therapy in patients with chronic hepatitis B virus infection. Hepatology. Mar. 1999;29(3):971-5. Less than 1000 patients and not US study. [pmid: 10051505].
281 Lin X, Qian GS, Lu PX, Wu L, Wen YM. Full-length genomic analysis of hepatitis B virus isolates in a patient progressing from hepatitis to hepatocellular carcinoma. Journal of Medical Virology. Jul. 2001;64(3):299-304. Not relevant outcomes.
282 Lin X, Qian GS, Lu PX, Wu L, Wen YM, Lin X, et al. Full-length genomic analysis of hepatitis B virus isolates in a patient progressing from hepatitis to hepatocellular carcinoma. Journal of Medical Virology. Aug. 2001;64(4):299-304. Not relevant outcomes.
283 Lincoln D, Petoumenos K, Dore GJ, Lincoln D, Petoumenos K. Australian HIVOD, et al. HIV/HBV and HIV/HCV coinfection, and outcomes following highly active antiretroviral therapy. HIV Medicine. Jul. 2003;4(3):241-9. Not eligible target population. [pmid: 12859323].
284 Liu CJ, Chen PJ, Shau WY, Kao JH, Lai MY, Chen DS, et al. Clinical aspects and outcomes of volunteer blood donors testing positive for hepatitis-C virus infection in Taiwan: a prospective study. Liver International. Jun. 2003;23(3):148-55. Not eligible exposure. [pmid: 12955877].
285 Livingston SE, Simonetti JP, Bulkow LR, Homan CE, Snowball MM, Cagle HH, et al. Clearance of hepatitis B e antigen in patients with chronic hepatitis B and genotypes A, B, C, D, and F. Gastroenterology. Nov. 2007;133(5):1452-7. Not relevant outcomes. [pmid: 17920063].
286 Lo KJ, Tong MJ, Chien MC, Tsai YT, Liaw YF, Yang KC, et al. The natural course of hepatitis B surface antigen-positive chronic active hepatitis in Taiwan. J Infect Dis. Aug. 1982;146(2):205-10. Less than 1000 patients and not US study. [pmid: 6180031].
287 Lo MK, Lee KF, Chan NN, Leung WY, Ko GT, Chan WB, et al. Effects of gender, Helicobacter pylori and hepatitis B virus serology status on cardiovascular and renal complications in Chinese type 2 diabetic patients with overt nephropathy. Diabetes Obes Metab. May. 2004;6(3):223-30. Not eligible target population. [pmid: 15056131].
288 Locasciulli A, Alberti A, de Bock R, Cordonnier C, Einsele H, Engelhard D, et al. Impact of liver disease and hepatitis infections on allogeneic bone marrow transplantation in Europe: a survey from the European Bone Marrow Transplantation (EBMT) Group—Infectious Diseases Working Party. Bone Marrow Transplant. Nov. 1994;14(5):833-7. Not relevant outcomes. [pmid: 7534164].
289 Locasciulli A, Testa M, Valsecchi MG, Bacigalupo A, Solinas S, Tomas JF, et al. The role of hepatitis C and B virus infections as risk factors for severe liver complications following allogeneic BMT: a prospective study by the Infectious Disease Working Party of the European Blood and Marrow Transplantation Group. Transplantation. Nov 27. 1999;68(10):1486-91. Not eligible target population. [pmid: 10589944].
290 Lok AS, Lai CL, Chung HT, Lau JY, Leung EK, Wong LS, et al. Morbidity and mortality from chronic hepatitis B virus infection in family members of patients with malignant and nonmalignant hepatitis B virus-related chronic liver diseases. Hepatology. May. 1991;13(5):834-7. Not eligible target population. [pmid: 1709410].
291 Lok AS, Lai CL, Lok AS, Lai CL. alpha-Fetoprotein monitoring in Chinese patients with chronic hepatitis B virus infection: role in the early detection of hepatocellular carcinoma. Hepatology. Jan. 1989;9(1):110-5. Less than 1000 patients and not US study. [pmid: 2461890].
292 Lok AS, Liang RH, Chiu EK, Wong KL, Chan TK, Todd D, et al. Reactivation of hepatitis B virus replication in patients receiving cytotoxic therapy. Report of a prospective study. Gastroenterology. Jan. 1991;100(1):182-8. Not eligible target population. [pmid: 1983820].
293 Lok AS, Lok ASF. Prevention of hepatitis B virus-related hepatocellular carcinoma. Gastroenterology. Nov. 2004;127(5 Suppl 1):S303-9. Review. [pmid: 15508098].
294 Lok AS, Wong A, Sporton S, Lai CL, Liu V, Chung HT, et al. Hepatitis D virus superinfection remains a rare occurrence in non-drug abusers in Hong Kong. Journal of Hepatology. Mar. 1992;14(23):332-4. Not eligible exposure. [pmid: 1500697].
295 Loomba R, Rowley A, Wesley R, Liang TJ, Hoofnagle JH, Pucino F, et al. Systematic review: the effect of preventive lamivudine on hepatitis B reactivation during chemotherapy. Annals of Internal Medicine. Apr 1. 2008;148(7):519-28. Review. [pmid: 18378948].
296 Mackenjee MK, Coovadia HM, Mackenjee MK, Coovadia HM. Chronic liver disease in black children in Durban, South Africa. Ann Trop Paediatr. Sep. 1984;4(3):165-9. Not eligible target population. [pmid: 6084464].
297 Madayag RM, Johnson LB, Bartlett ST, Schweitzer EJ, Constantine NT, McCarter RJ Jr, et al. Use of renal allografts from donors positive for hepatitis B core antibody confers minimal risk for subsequent development of clinical hepatitis B virus disease. Transplantation. Dec 27. 1997;64(12):1781-6. Not relevant outcomes. [pmid: 9422420].
298 Mahmood S, Niiyama G, Kamei A, Izumi A, Nakata K, Ikeda H, et al. Influence of viral load and genotype in the progression of Hepatitis B-associated liver cirrhosis to hepatocellular carcinoma. Liver International. Apr. 2005;25(2):220-5. Less than 1000 patients and not US study. [pmid: 15780042].
299 Maida I, Soriano V, Castellares C, Ramos B, Sotgiu G, Martin-Carbonero L, et al. Liver fibrosis in HIV-infected patients with chronic hepatitis B extensively exposed to antiretroviral therapy with anti-HBV activity. HIV Clin Trials. Sep–Oct. 2006;7(5):246-50. Not eligible target population. [pmid: 17162318].
300 Majda-Stanislawska E, Bednarek M, Kuydowicz J, Majda-Stanislawska E, Bednarek M, Kuydowicz J. Immunogenicity of inactivated hepatitis A vaccine in children with chronic liver disease. Pediatr Infect Dis J. Jun. 2004;23(6):571-4. Not eligible target population. [pmid: 15194843].
301 Malathi S, Mohanavalli B, Menon T, Srilatha P, Sankaranarayanan VS, Raju BB, et al. Clinical and viral marker pattern of acute sporadic hepatitis in children in Madras, South India. J Trop Pediatr. Oct. 1998;44(5):275-8. Not eligible target population. [pmid: 9819489].
302 Malkan G, Cattral MS, Humar A, Al Asghar H, Greig PD, Hemming AW, et al. Lamivudine for hepatitis B in liver transplantation: a single-center experience. Transplantation. Apr 15. 2000;69(7):1403-7. Not eligible target population. [pmid: 10798762].
303 Maluf DG, Stravitz RT, Williams B, Cotterell AH, Mas VR, Heuman D, et al. Multimodality therapy and liver transplantation in patients with cirrhosis and hepatocellular carcinoma: 6 years, single-center experience. Transplant Proc. Jan–Feb. 2007;39(1):153-9. Not eligible exposure. [pmid: 17275495].
304 Mancuso A, Sciarrino E, Renda MC, Maggio A, Mancuso A, Sciarrino E, et al. A prospective study of hepatocellular carcinoma incidence in thalassemia. Hemoglobin. 2006;30(1):119-24. Not eligible exposure. [pmid: 16540424].
305 Mandelbrot L, Mandelbrot L. Vertical transmission of viral infections. Curr Opin Obstet Gynecol. Apr. 1998;10(2):123-8. Review. [pmid: 9551307].
306 Mangia A, Schiavone G, Lezzi G, Marmo R, Bruno F, Villani MR, et al. HCV and diabetes mellitus: evidence for a negative association. American Journal of Gastroenterology. Dec. 1998;93(12):2363-7. Not eligible exposure. [pmid: 9860393].
307 Manno M, Camma C, Schepis F, Bassi F, Gelmini R, Giannini F, et al. Natural history of chronic HBV carriers in northern Italy: morbidity and mortality after 30 years. Gastroenterology. Sep. 2004;127(3):756-63. Less than 1000 patients and not US study. [pmid: 15362032].
308 Marcellin P, Castelnau C, Martinot-Peignoux M, Boyer N, Marcellin P, Castelnau C, et al. Natural history of hepatitis B. Minerva Gastroenterologica e Dietologica. Mar. 2005;51(1):63-75. Review. [pmid: 15756147].
309 Marchesini G, Zoli M, Angiolini A, Feliciangeli G, Santoro A, Ferroni P, et al. Relevance of HBe/anti-HBe system and DNA polymerase activity in chronic hepatitis-B virus carriers on haemodialysis. A prospective study. Nephron. 1981;29(12):44-8. Not eligible target population. [pmid: 7329473].
310 Maria Elzbieta SL, Marek LD, Maria Elzbieta SL, Marek LD. Histological outcome of chronic hepatitis B in children treated with interferon alpha. World J Gastroenterol. Dec 7. 2005;11(45):7179-82. Not eligible target population. [pmid: 16437668].
311 Mariscal LF, Rodriguez-Inigo E, Bartolome J, Castillo I, Ortiz-Movilla N, Navacerrada C, et al. Hepatitis B infection of the liver in chronic hepatitis C without detectable hepatitis B virus DNA in serum. Journal of Medical Virology. Jun. 2004;73(2):177-86. Not eligible target population. [pmid: 15122790].
312 Markovic S, Drozina G, Vovk M, Fidler-Jenko M, Markovic S, Drozina G, et al. Reactivation of hepatitis B but not hepatitis C in patients with malignant lymphoma and immunosuppressive therapy. A prospective study in 305 patients. Sep–Oct. 1999;46(29):2925-30. Not relevant outcomes.
313 Marotta F, Vangieri B, Cecere A, Gattoni A, Marotta F, Vangieri B, et al. The pathogenesis of hepatocellular carcinoma is multifactorial event. Novel immunological treatment in prospect. Clin Ter. May. 2004;155(5):187-99. Not eligible target population. [pmid: 15344567].
314 Marzano A, Debernardi-Venon W, Smedile A, Brunetto MR, Torrani Cerenzia MR, Actis GC, et al. Recurrence of hepatitis B in liver transplants treated with antiviral therapy. Ital J Gastroenterol. Feb. 1998;30(1):77-81. Not eligible target population.
315 Mathews G, Bhagani S, Mathews G, Bhagani S. The epidemiology and natural history of HIV/HBV and HIV/HCV co-infections. J HIV Ther. Nov. 2003;8(4):77-84. Review. [pmid: 14671504].
316 Mathur S, Mathur M, Bhandari R, Banerjee K, Kothari D, Mathur A, et al. A study of the prevalence of hepatitis B surface antigen (HBsAg) in cirrhosis of liver by RPHA. J Assoc Physicians India. Nov. 1985;33(11):714. Not relevant outcomes. [pmid: 4093384].
317 Mendez-Sanchez N, Aguilar-Ramirez JR, Reyes A, Dehesa M, Juorez A, Castneda B, et al. Etiology of liver cirrhosis in Mexico. Ann Hepatol. Jan–Mar. 2004;3(1):30-3. Not relevant outcomes. [pmid: 15118577].
318 Ming L, Thorgeirsson SS, Gail MH, Lu P, Harris CC, Wang N, et al. Dominant role of hepatitis B virus and cofactor role of aflatoxin in hepatocarcinogenesis in Qidong, China. Hepatology. Nov. 2002;36(5):1214-20. Not eligible target population. [pmid: 12395332].
319 Miyakawa H, Izumi N, Marumo F, Sato C, Miyakawa H, Izumi N, et al. Roles of alcohol, hepatitis virus infection, and gender in the development of hepatocellular carcinoma in patients with liver cirrhosis. Alcohol Clin Exp Res. Feb. 1996;20(1 Suppl):91A-4A. Less than 1000 patients and not US study.
320 Mocroft A, Soriano V, Rockstroh J, Reiss P, Kirk O, de Wit S, et al. Is there evidence for an increase in the death rate from liver-related disease in patients with HIV?. AIDS. Dec 2. 2005;19(18):2117-25. Not eligible exposure. [pmid: 16284461].
321 Mohamadnejad M, Montazeri G, Fazlollahi A, Zamani F, Nasiri J, Nobakht H, et al. Noninvasive markers of liver fibrosis and inflammation in chronic hepatitis B-virus related liver disease. American Journal of Gastroenterology. Nov. 2006;101(11):2537-45. Not relevant outcomes. [pmid: 17029616].
322 Mohamed AE, al Karawi MA, al Otaibi R, Hanid MA, Mohamed AE, al Karawi MA, et al. Results of sclerotherapy in 100 patients comparison of the outcome between schistosomiasis and hepatitis B. Hepato-Gastroenterology. Oct. 1989;36(5):333-6. Less than 1000 patients and not US study. [pmid: 2620900].
323 Mohamed AE, Kew MC, Groeneveld HT. Alcohol consumption as a risk factor for hepatocellular carcinoma in urban southern African blacks. Int J Cancer. Jun 19. 1992;51(4):537-41. Not eligible exposure. [pmid: 1318267].
324 Mohsen AH, Mohsen AH. Trent HCVSG, Trent HCVSG. The epidemiology of hepatitis C in a UK health regional population of 5.12 million. Gut. May. 2001;48(5):707-13. Not eligible exposure. [pmid: 11302973].
325 Mok TS, Yu SC, Lee C, Sung J, Leung N, Lai P, et al. False-negative rate of abdominal sonography for detecting hepatocellular carcinoma in patients with hepatitis B and elevated serum alpha-fetoprotein levels. AJR Am J Roentgenol. Aug. 2004;183(2):453-8. Not relevant outcomes. [pmid: 15269040].
326 Momosaki S, Nakashima Y, Kojiro M, Tabor E, Momosaki S, Nakashima Y, et al. HBsAg-negative hepatitis B virus infections in hepatitis C virus-associated hepatocellular carcinoma. Journal of Viral Hepatitis. May. 2005;12(3):325-9. Not relevant outcomes. [pmid: 15850475].
327 Muroyama R, Kato N, Yoshida H, Otsuka M, Moriyama M, Wang Y, et al. Nucleotide change of codon 38 in the X gene of hepatitis B virus genotype C is associated with an increased risk of hepatocellular carcinoma. Journal of Hepatology. Dec. 2006;45(6):805-12. Not relevant outcomes. [pmid: 17050029].
328 Myung SJ, Yoon JH, Kim KM, Gwak GY, Kim YJ, Yu JW, et al. Diffuse infiltrative hepatocellular carcinomas in a hepatitis B-endemic area: diagnostic and therapeutic impediments. Hepato-Gastroenterology. Mar–Apr. 2006;53(68):266-70. Not relevant outcomes. [pmid: 16608037].
329 Nakayoshi T, Maeshiro T, Nakayoshi T, Nakasone H, Sakugawa H, Kinjo F, et al. Difference in prognosis between patients infected with hepatitis B virus with genotype B and those with genotype C in the Okinawa Islands: a prospective study. Journal of Medical Virology. Jul. 2003;70(3):350-4. Less than 1000 patients and not US study. [pmid: 12766996].
330 Natov SN, Pereira BJ, Natov SN, Pereira BJG. Transmission of viral hepatitis by kidney transplantation: donor evaluation and transplant policies (Part 1: hepatitis B virus). Transpl Infect Dis. Sep. 2002;4(3):117-23. Review. [pmid: 12421455].
331 Ndiritu M, Cowgill KD, Ismail A, Chiphatsi S, Kamau T, Fegan G, et al. Immunization coverage and risk factors for failure to immunize within the Expanded Programme on Immunization in Kenya after introduction of new Haemophilus influenzae type b and hepatitis b virus antigens. BMC Public Health. 2006;6:132. Not eligible target population. [pmid: 16707013].
332 Ndububa DA, Ojo OS, Adeodu OO, Adetiloye VA, Olasode BJ, Famurewa OC, et al. Primary hepatocellular carcinoma in Ile-Ife, Nigeria: a prospective study of 154 cases. Niger J Med. Apr–Jun. 2001;10(2):59-63. Not eligible target population. [pmid: 11705059].
333 Neff GW, Nery J, Lau DT, O'Brien CB, Duncan R, Shire NJ, et al. Tenofovir therapy for lamivudine resistance following liver transplantation. Ann Pharmacother. Dec. 2004;38(12):1999-2004. Not relevant outcomes. [pmid: 15507498].
334 Negro F, Baldi M, Bonino F, Rocca G, Demartini A, Passarino G, et al. Chronic HDV (hepatitis delta virus) hepatitis. Intrahepatic expression of delta antigen, histologic activity and outcome of liver disease. Journal of Hepatology. Feb. 1988;6(1):8-14. Not eligible exposure. [pmid: 3346535].
335 Ng IO, Poon RT, Shek TW, Fan ST, Ng IOL, Poon RTP, et al. Clinicopathologic and prognostic significance of the histologic activity of noncancerous liver tissue in hepatitis B virus-associated hepatocellular carcinoma. Am J Clin Pathol. Mar. 2002;117(3):411-8. Not eligible target population. [pmid: 11892725].
336 Ng YY, Lin CC, Wu SC, Hwang SJ, Ho CH, Yang WC, et al. Leukopenia and thrombocytopenia in hemodialysis patients with hepatitis B or C virus infection and non-hemodialysis patients with hepatitis cirrhosis. Clin Nephrol. Apr. 2002;57(4):289-95. Not eligible exposure. [pmid: 12005245].
337 Niederau C, Heintges T, Lange S, Goldmann G, Niederau CM, Mohr L, et al. Long-term follow-up of HBeAg-positive patients treated with interferon alfa for chronic hepatitis B. N Engl J Med. May 30. 1996;334(22):1422-7. Less than 1000 patients and not US study. [pmid: 8618580].
338 Nishiura T, Watanabe H, Ito M, Matsuoka Y, Yano K, Daikoku M, et al. Ultrasound evaluation of the fibrosis stage in chronic liver disease by the simultaneous use of low and high frequency probes. Br J Radiol. Mar. 2005;78(927):189-97. Not eligible exposure. [pmid: 15730982].
339 Norder H, Brattstrom C, Magnius L, Norder H, Brattstrom C, Magnius L. High frequency of hepatitis B virus DNA in anti-HBe positive sera on longitudinal follow-up of patients with renal transplants and chronic hepatitis B. Journal of Medical Virology. Apr. 1989;27(4):322-8. Not eligible target population. [pmid: 2656911].
340 Obata H, Hayashi N, Motoike Y, Hisamitsu T, Okuda H, Kobayashi S, et al. A prospective study on the development of hepatocellular carcinoma from liver cirrhosis with persistent hepatitis B virus infection. Int J Cancer. Jun 15. 1980;25(6):741-7. Less than 1000 patients and not US study. [pmid: 14768703].
341 Obika M, Shinji T, Fujioka S, Terada R, Ryuko H, Lwin AA, et al. Hepatitis B virus DNA in liver tissue and risk for hepatocarcinogenesis in patients with hepatitis C virus-related chronic liver disease. A prospective study. Intervirology. 2008;51(1):59-68. Less than 1000 patients and not US study. [pmid: 18349544].
342 Okeke EN, Malu AO, Obafunwa JO, Nwana EJ, Okeke EN, Malu AO, et al. Aetiological significance of alcohol in liver cirrhosis on the Jos Plateau. West Afr J Med. Jan–Mar. 2002;21(1):12-4. Not eligible exposure. [pmid: 12081334].
343 Oldakowska-Jedynak U, Paczek L, Foroncewicz B, Mucha K, Nyckowski P, Zieniewicz K, et al. Prevention of hepatitis B recurrence after liver transplantation using lamivudine and hepatitis B immune globulin. Annals of Transplantation. 2007;12(3):28-32. Not eligible target population. [pmid: 18290567].
344 Oliveri F, Colombatto P, Derenzini M, Trere D, Papotti M, David E, et al. Hepatocellular carcinoma: pathogenetic implications of the hepatitis delta virus. Prog Clin Biol Res. 1993;382:165-70. Not eligible exposure. [pmid: 8389050].
345 Oon CJ, Yo SL, Chio LF, Chan SH, Oon CJ, Yo SL, et al. A pilot study on the screening of primary hepatocellular carcinoma in selected high risk groups in the population using multiple tumour markers. Ann Acad Med Singapore. Apr. 1980;9(2):240-4. Less than 1000 patients and not US study. [pmid: 6252815].
346 Osborn MK, Guest JL, Rimland D. Hepatitis B virus and HIV coinfection: relationship of different serological patterns to survival and liver disease. HIV Medicine. Jul. 2007;8(5):271-9. Not relevant outcomes. [pmid: 17561872].
347 Osborn MK, Han SH, Regev A, Bzowej NH, Ishitani MB, Tran TT, et al. Outcomes of patients with hepatitis B who developed antiviral resistance while on the liver transplant waiting list. Clinical Gastroenterology & Hepatology. Dec. 2007;5(12):1454-61. Not eligible target population. [pmid: 17977800].
348 Ostapowicz G, Fontana RJ, Schiodt FV, Larson A, Davern TJ, Han SH, et al. Results of a prospective study of acute liver failure at 17 tertiary care centers in the United States. Annals of Internal Medicine. Dec 17. 2002;137(12):947-54. Not eligible target population. [pmid: 12484709].
349 Otedo AE, Otedo AEO. HBV, HIV co-infection at Kisumu District Hospital, Kenya. East Afr Med J. Dec. 2004;81(12):626-30. Not relevant outcomes. [pmid: 15868977].
350 Otegbayo JA, Arinola OG, Aje A, Oluwasola OA, Okiwelu OH, Salimonu LS, et al. Usefulness of acute phase proteins for monitoring development of hepatocellular carcinoma in hepatitis B virus carriers. West Afr J Med. Apr–Jun. 2005;24(2):124-7. Less than 1000 patients and not US study. [pmid: 16092312].
351 Oton E, Barcena R, Garcia-Garzon S, Moreno-Zamora A, Moreno A, Garcia-Gonzalez M, et al. Pegylated interferon and ribavirin for the recurrence of chronic hepatitis C genotype 1 in transplant patients. Transplant Proc. Nov. 2005;37(9):3963-4. Not eligible exposure. [pmid: 16386597].
352 Pan JJ, Yang CF, Chu CJ, Chang FY, Lee SD. Prediction of liver fibrosis in patients with chronic hepatitis B by serum markers. Hepato-Gastroenterology. Jul–Aug. 2007;54(77):1503-6. Not relevant outcomes. [pmid: 17708285].
353 Papatheodoridis GV, Manesis E, Hadziyannis SJ, Papatheodoridis GV, Manesis E, Hadziyannis SJ. The long-term outcome of interferon-alpha treated and untreated patients with HBeAg-negative chronic hepatitis B. Journal of Hepatology. Feb. 2001;34(2):306-13. Less than 1000 patients and not US study. [pmid: 11281561].
354 Papatheodoridis GV, Petraki K, Cholongitas E, Kanta E, Ketikoglou I, Manesis EK, et al. Impact of interferon-alpha therapy on liver fibrosis progression in patients with HBeAg-negative chronic hepatitis B.[erratum appears in J Viral Hepat. 2005 Jul;12(4):443]. Journal of Viral Hepatitis. Mar. 2005;12(2):199-206. Less than 1000 patients and not US study. [pmid: 15720536].
355 Parfrey PS, Forbes RD, Hutchinson TA, Beaudoin JG, Dauphinee WD, Hollomby DJ, et al. The clinical and pathological course of hepatitis B liver disease in renal transplant recipients. Transplantation. May. 1984;37(5):461-6. Not eligible target population. [pmid: 6375001].
356 Parfrey PS, Forbes RD, Hutchinson TA, Kenick S, Farge D, Dauphinee WD, et al. The impact of renal transplantation on the course of hepatitis B liver disease. Transplantation. Jun. 1985;39(6):610-5. Not eligible target population. [pmid: 3890290].
357 Park BL, Kim YJ, Cheong HS, Kim LH, Choi YH, Lee HS, et al. Association of common promoter polymorphisms of MCP1 with hepatitis B virus clearance. Exp Mol Med. Dec 31. 2006;38(6):694-702. Not relevant outcomes. [pmid: 17202846].
358 Park BL, Lee HS, Kim YJ, Kim JY, Jung JH, Kim LH, et al. Association between interleukin 6 promoter variants and chronic hepatitis B progression. Exp Mol Med. Apr 30. 2003;35(2):76-82. Not relevant outcomes. [pmid: 12754410].
359 Park JW, An M, Choi JI, Kim YI, Kim SH, Lee WJ, et al. Accuracy of clinical criteria for the diagnosis of hepatocellular carcinoma without biopsy in a Hepatitis B virus-endemic area. Journal of Cancer Research & Clinical Oncology. Dec. 2007;133(12):937-43. Not relevant outcomes. [pmid: 17516087].
360 Park JW, Park KW, Cho SH, Park HS, Lee WJ, Lee DH, et al. Risk of hepatitis B exacerbation is low after transcatheter arterial chemoembolization therapy for patients with HBV-related hepatocellular carcinoma: report of a prospective study. American Journal of Gastroenterology. Oct. 2005;100(10):2194-200. Not eligible target population. [pmid: 16181368].
361 Park KW, Park JW, Choi JI, Kim TH, Kim SH, Park HS, et al. Survival analysis of 904 patients with hepatocellular carcinoma in a hepatitis B virus-endemic area. Journal of Gastroenterology & Hepatology. Mar. 2008;23(3):467-73. Less than 1000 patients and not US study. [pmid: 17764529].
362 Park SJ, Paik SW, Choi MS, Lee JH, Koh KC, Kim SJ, et al. Is lamivudine with 1-week HBlg as effective as long-term high-dose HBlg in HBV prophylaxis after liver transplantation?. Transplant Proc. Jun. 2002;34(4):1252-4. Not eligible target population. [pmid: 12072331].
363 Parrish KM, Higuchi S, Muramatsu T, Stinson FS, Harford TC, Parrish KM, et al. A method for estimating alcohol-related liver cirrhosis mortality in Japan. International Journal of Epidemiology. Dec. 1991;20(4):921-6. Not eligible exposure. [pmid: 1800431].
364 Patana M, Nyazema NZ, Ndamba J, Munatsi A, Tobaiwa O, Patana M, et al. Schistosomiasis and hepatitis B infection in pregnancy: implications for vaccination against hepatitis B. Cent Afr J Med. Sep. 1995;41(9):288-92. Not eligible target population. [pmid: 8591639].
365 Paterlini P, Driss F, Nalpas B, Pisi E, Franco D, Berthelot P, et al. Persistence of hepatitis B and hepatitis C viral genomes in primary liver cancers from HBsAg-negative patients: a study of a low-endemic area. Hepatology. Jan. 1993;17(1):20-9. Not relevant outcomes. [pmid: 8380790].
366 Pessione F, Ramond MJ, Peters L, Pham BN, Batel P, Rueff B, et al. Five-year survival predictive factors in patients with excessive alcohol intake and cirrhosis. Effect of alcoholic hepatitis, smoking and abstinence. Liver International. Feb. 2003;23(1):45-53. Not relevant outcomes. [pmid: 12640727].
367 Peters MG, Andersen J, Lynch P, Liu T, Alston-Smith B, Brosgart CL, et al. Randomized controlled study of tenofovir and adefovir in chronic hepatitis B virus and HIV infection: ACTG A5127. Hepatology. Nov. 2006;44(5):1110-6. Not relevant outcomes. [pmid: 17058225].
368 Pett SL, Wand H, Law MG, Arduino R, Lopez JC, Knysz B, et al. Evaluation of Subcutaneous Proleukin (interleukin-2) in a Randomized International Trial (ESPRIT): geographical and gender differences in the baseline characteristics of participants. HIV Clin Trials. Mar–Apr. 2006;7(2):70-85. Not relevant outcomes. [pmid: 16798622].
369 Piao CY, Fujioka S, Iwasaki Y, Fujio K, Kaneyoshi T, Araki Y, et al. Lamivudine treatment in patients with HBV-related hepatocellular carcinoma—using an untreated, matched control cohort. Acta Med Okayama. Oct. 2005;59(5):217-24. Not eligible target population. [pmid: 16286955].
370 Picardi M, Pane F, Quintarelli C, De Renzo A, Del Giudice A, De Divitiis B, et al. Hepatitis B virus reactivation after fludarabine-based regimens for indolent non-Hodgkin's lymphomas: high prevalence of acquired viral genomic mutations. Haematologica. Nov. 2003;88(11):1296-303. Not relevant outcomes. [pmid: 14607759].
371 Pineda JA, Santos J, Rivero A, Abdel-Kader L, Palacios R, Camacho A, et al. Liver toxicity of antiretroviral combinations including atazanavir/ritonavir in patients co-infected with HIV and hepatitis viruses: impact of pre-existing liver fibrosis. Journal of Antimicrobial Chemotherapy. Apr. 2008;61(4):925-32. Not relevant outcomes. [pmid: 18276600].
372 Pinney SP, Cheema FH, Hammond K, Chen JM, Edwards NM, Mancini D, et al. Acceptable recipient outcomes with the use of hearts from donors with hepatitis-B core antibodies. J Heart Lung Transplant. Jan. 2005;24(1):34-7. Not eligible target population. [pmid: 15653376].
373 Podda M, Roncalli M, Battezzati PM, Borzio M, Bruno S, Servida E, et al. Liver-cell dysplasia and hepatocellular carcinoma. Ital J Gastroenterol. Jan. 1992;24(1):39-42. Review. [pmid: 1315175].
374 Pontisso P, Belluco C, Bertorelle R, De Moliner L, Chieco-Bianchi L, Nitti D, et al. Hepatitis C virus infection associated with human hepatocellular carcinoma: lack of correlation with p53 abnormalities in Caucasian patients. Cancer. Oct 15. 1998;83(8):1489-94. Not eligible exposure. [pmid: 9781942].
375 Poon RT, Fan ST, Lo CM, Liu CL, Lam CM, Yuen WK, et al. Extended hepatic resection for hepatocellular carcinoma in patients with cirrhosis: is it justified?. Ann Surg. Nov. 2002;236(5):602-11. Not eligible exposure. [pmid: 12409666].
376 Poon RT, Fan ST, Lo CM, Liu CL, Ng IO, Wong J, et al. Long-term prognosis after resection of hepatocellular carcinoma associated with hepatitis B-related cirrhosis. J Clin Oncol. Mar. 2000;18(5):1094-101. Less than 1000 patients and not US study. [pmid: 10694562].
377 Pozzi M, Grassi G, Ratti L, Favini G, Dell'Oro R, Redaelli E, et al. Cardiac, neuroadrenergic, and portal hemodynamic effects of prolonged aldosterone blockade in postviral child A cirrhosis. American Journal of Gastroenterology. May. 2005;100(5):1110-6. Not eligible exposure. [pmid: 15842586].
378 Pramoolsinsup C, Pramoolsinsup C. Management of viral hepatitis B. Journal of Gastroenterology & Hepatology. Feb. 2002;17(Suppl):S125-45. Review. [pmid: 12000599].
379 Prentice RL, Prentice RL. Epidemiologic data on exogenous hormones and hepatocellular carcinoma and selected other cancers. Prev Med. Jan. 1991;20(1):38-46. Review. [pmid: 1848935].
380 Puoti M, Cozzi-Lepri A, Ancarani F, Bruno R, Ambu S, Ferraro T, et al. The management of hepatitis B virus/HIV-1 co-infected patients starting their first HAART regimen. Treating two infections for the price of one drug?. Antiviral Therapy. Oct. 2004;9(5):811-7. Not eligible target population. [pmid: 15535419].
381 Puoti M, Cozzi-Lepri A, Arici C, Moller NF, Lundgren JD, Ledergerber B, et al. Impact of lamivudine on the risk of liver-related death in 2,041 HBsAg- and HIV-positive individuals: results from an inter-cohort analysis. Antiviral Therapy. 2006;11(5):567-74. Not eligible target population. [pmid: 16964824].
382 Puoti M, Spinetti A, Ghezzi A, Donato F, Zaltron S, Putzolu V, et al. Mortality for liver disease in patients with HIV infection: a cohort study. Journal of Acquired Immune Deficiency Syndromes: JAIDS. Jul 1. 2000;24(3):211-7. Not eligible exposure.
383 Puschel K, Puschel K. Drug-related death—an update. Forensic Sci Int. Nov. 1993;62(12):121-8. Not eligible exposure. [pmid: 8300023].
384 Qureshi H, Ahsan T, Mujeeb SA, Jawad F, Mehdi I, Ahmed W, et al. Diabetes mellitus is equally frequent in chronic HCV and HBV infection. JPMA J Pak Med Assoc. Jul. 2002;52(7):280-3. Not relevant outcomes. [pmid: 12481656].
385 Rabe C, Pilz T, Klostermann C, Berna M, Schild HH, Sauerbruch T, et al. Clinical characteristics and outcome of a cohort of 101 patients with hepatocellular carcinoma. World J Gastroenterol. Apr. 2001;7(2):208-15. Not eligible exposure. [pmid: 11819762].
386 Ragni MV, Belle SH, Im K, Neff G, Roland M, Stock P, et al. Survival of human immunodeficiency virus-infected liver transplant recipients. J Infect Dis. Nov 15. 2003;188(10):1412-20. Not eligible exposure. [pmid: 14624365].
387 Raguin G, Rosenthal E, Cacoub P, Veyssier P, Piette JC, Micoud M, et al. Hepatitis C in France: a national survey in the Departments of Internal Medicine and Infectious Diseases. The GERMIVIC (Joint Study Group on Hepatitis C virus of the French National Society of Internal Medicine and the French Society of Infectious Diseases). Eur J Epidemiol. Sep. 1998;14(6):545-8. Not eligible exposure. [pmid: 9794120].
388 Raptis I, Koskinas J, Emmanouil T, Hadziyannis S, Raptis I, Koskinas J, et al. Changing relative roles of hepatitis B and C viruses in the aetiology of hepatocellular carcinoma in Greece. Epidemiological and clinical observations. Journal of Viral Hepatitis. Nov. 2003;10(6):450-4. Not relevant outcomes. [pmid: 14633179].
389 Realdi G, Fattovich G, Hadziyannis S, Schalm SW, Almasio P, Sanchez-Tapias J, et al. Survival and prognostic factors in 366 patients with compensated cirrhosis type B: a multicenter study. The Investigators of the European Concerted Action on Viral Hepatitis (EUROHEP). Journal of Hepatology. Oct. 1994;21(4):656-66. Less than 1000 patients and not US study. [pmid: 7814813].
390 Revill PA, Littlejohn M, Ayres A, Yuen L, Colledge D, Bartholomeusz A, et al. Identification of a novel hepatitis B virus precore/core deletion mutant in HIV/hepatitis B virus co-infected individuals. AIDS. Aug 20. 2007;21(13):1701-10. Not relevant outcomes. [pmid: 17690567].
391 Rhee KJ, Albertson TE, Kizer KW, Burns MJ, Hughes MJ, Ascher MS, et al. A comparison of HIV-1, HBV, and HTLV-I/II seroprevalence rates of injured patients admitted through California emergency departments. Ann Emerg Med. Apr. 1992;21(4):397-401. Not relevant outcomes. [pmid: 1554177].
392 Rinaldi M, Cagnacci A, Pansini FE, de Aloysio D, Sgarabotto MP, Bacchi-Modena A, et al. Neutral effect of prolonged transdermal hormone therapy on liver function of postmenopausal women with chronic active hepatitis. Menopause. Sep–Oct. 2005;12(5):619-22. Not relevant outcomes. [pmid: 16145317].
393 Ristig MB, Crippin J, Aberg JA, Powderly WG, Lisker-Melman M, Kessels L, et al. Tenofovir disoproxil fumarate therapy for chronic hepatitis B in human immunodeficiency virus/hepatitis B virus-coinfected individuals for whom interferon-alpha and lamivudine therapy have failed. J Infect Dis. Dec 15. 2002;186(12):1844-7. Not relevant outcomes. [pmid: 12447773].
394 Rockstroh JK, Rockstroh JK. Influence of viral hepatitis on HIV infection. Journal of Hepatology. 2006;44(1 Suppl):S25-7. Review. [pmid: 16338020].
395 Rodriguez-Diaz JL, Rosas-Camargo V, Vega-Vega O, Morales-Espinosa D, Mendez-Reguera A, Martinez-Tlahuel JL, et al. Clinical and pathological factors associated with the development of hepatocellular carcinoma in patients with hepatitis virus-related cirrhosis: a long-term follow-up study. Clin Oncol (R Coll Radiol). Apr. 2007;19(3):197-203. Less than 1000 patients and not US study. [pmid: 17359907].
396 Rodriguez-Frias F, Jardi R, Buti M, Schaper M, Hermosilla E, Valdes A, et al. Hepatitis B virus genotypes and G1896A precore mutation in 486 Spanish patients with acute and chronic HBV infection. Journal of Viral Hepatitis. May. 2006;13(5):343-50. Not relevant outcomes. [pmid: 16637866].
397 Rousou J, Levitsky S, Gonzalez-Lavin L, Cosgrove D, Magilligan D, Weldon C, et al. Randomized clinical trial of fibrin sealant in patients undergoing resternotomy or reoperation after cardiac operations. A multicenter study. J Thorac Cardiovasc Surg. Feb. 1989;97(2):194-203. Not eligible exposure. [pmid: 2464722].
398 Rozario R, Ramakrishna B, Rozario R, Ramakrishna B. Histopathological study of chronic hepatitis B and C: a comparison of two scoring systems. Journal of Hepatology. Feb. 2003;38(2):223-9. Not relevant outcomes. [pmid: 12547412].
399 Ryder RW, Ryder RW. Hepatitis B virus vaccine in The Gambia, West Africa: synergy between public health research and practice. Mt Sinai J Med. Nov. 1992;59(6):487-92. Not eligible target population. [pmid: 1336128].
400 Ryder RW, Whittle HC, Sanneh AB, Ajdukiewicz AB, Tulloch S, Yvonnet B, et al. Persistent hepatitis B virus infection and hepatoma in The Gambia, west Africa. A case-control study of 140 adults and their 603 family contacts. Am J Epidemiol. Nov 1. 1992;136(9):1122-31. Not relevant outcomes. [pmid: 1334367].
401 Sadikali F, Sadikali F. Hepatitis-associated antigen and acute and chronic liver disease in Uganda. East Afr Med J. Oct. 1972;49(10):783-90. Not relevant outcomes. [pmid: 4666004].
402 Sadikali F, Sadikali F. The association of syphilis with cirrhosis: the role of alcohol and serum hepatitis. Postgrad Med J. Feb. 1975;51(592):69-73. Not relevant outcomes.
403 Sakuma K, Takahara T, Okuda K, Tsuda F, Mayumi M, Sakuma K, et al. Prognosis of hepatitis B virus surface antigen carriers in relation to routine liver function tests: a prospective study. Gastroenterology. Jul. 1982;83(1 Pt 1):114-7. Less than 1000 patients and not US study. [pmid: 7075936].
404 Samonakis DN, Cholongitas E, Thalheimer U, Kalambokis G, Quaglia A, Triantos CK, et al. Hepatic venous pressure gradient to assess fibrosis and its progression after liver transplantation for HCV cirrhosis. Liver Transpl. Sep. 2007;13(9):1305-11. Not eligible exposure. [pmid: 17763383].
405 Samuel D, Bismuth A, Mathieu D, Arulnaden JL, Reynes M, Benhamou JP, et al. Passive immunoprophylaxis after liver transplantation in HBsAg-positive patients. Lancet. Apr 6. 1991;337(8745):813-5. Not relevant outcomes. [pmid: 1672913].
406 Samuel D, Muller R, Alexander G, Fassati L, Ducot B, Benhamou JP, et al. Liver transplantation in European patients with the hepatitis B surface antigen. N Engl J Med. Dec 16. 1993;329(25):1842-7. Not relevant outcomes. [pmid: 8247035].
407 Saracco G, Rosina F, Brunetto MR, Amoroso P, Caredda F, Farci P, et al. Rapidly progressive HBsAg-positive hepatitis in Italy. The role of hepatitis delta virus infection. Journal of Hepatology. Dec. 1987;5(3):274-81. Less than 1000 patients and not US study. [pmid: 3429834].
408 Schiff ER, Lai CL, Hadziyannis S, Neuhaus P, Terrault N, Colombo M, et al. Adefovir dipivoxil therapy for lamivudine-resistant hepatitis B in pre- and post-liver transplantation patients. Hepatology. Dec. 2003;38(6):1419-27. Not eligible target population. [pmid: 14647053].
409 Schiodt FV, Davern TJ, Shakil AO, McGuire B, Samuel G, Lee WM, et al. Viral hepatitis-related acute liver failure. American Journal of Gastroenterology. Feb. 2003;98(2):448-53. Not relevant outcomes. [pmid: 12591067].
410 Schmidt LE, Wang LP, Hansen BA, Larsen FS, Schmidt LE, Wang LP, et al. Systemic hemodynamic effects of treatment with the molecular adsorbents recirculating system in patients with hyperacute liver failure: a prospective controlled trial. Liver Transpl. Mar. 2003;9(3):290-7. Not eligible exposure. [pmid: 12619027].
411 Schmitz KJ, Wohlschlaeger J, Lang H, Sotiropoulos GC, Malago M, Steveling K, et al. Activation of the ERK and AKT signalling pathway predicts poor prognosis in hepatocellular carcinoma and ERK activation in cancer tissue is associated with hepatitis C virus infection. Journal of Hepatology. Jan. 2008;48(1):83-90. Not eligible target population. [pmid: 17998146].
412 Semple D, Keogh J, Forni L, Venn R, Semple D, Keogh J, et al. Clinical review: Vasculitis on the intensive care unit — part 2: treatment and prognosis. Crit Care. Apr. 2005;9(2):193-7. Not eligible exposure. [pmid: 15774077].
413 Sene D, Pol S, Piroth L, Goujard C, Dellamonica P, Moussali J, et al. Hepatitis B virus-human immunodeficiency virus co-infection in France: a cross-sectional multicentre study. Epidemiol Infect. Apr. 2007;135(3):409-16. Not relevant outcomes. [pmid: 16863601].
414 Sharma YR, Miah AR, Saha SK, Mohammed S, Rahman M, Roy PK, et al. A study on efficacy of lamivudine therapy in decompensated cirrhosis of liver due to chronic hepatitis B virus infection. Nepal Med Coll J. Dec. 2004;6(2):106-11. Not relevant outcomes. [pmid: 16295739].
415 Sharp GB, Lagarde F, Mizuno T, Sauvaget C, Fukuhara T, Allen N, et al. Relationship of hepatocellular carcinoma to soya food consumption: a cohort-based, case-control study in Japan. Int J Cancer. Jun 10. 2005;115(2):290-5. Not relevant outcomes. [pmid: 15688396].
416 Sharp GB, Mizuno T, Cologne JB, Fukuhara T, Fujiwara S, Tokuoka S, et al. Hepatocellular carcinoma among atomic bomb survivors: significant interaction of radiation with hepatitis C virus infections. Int J Cancer. Feb 10. 2003;103(4):531-7. Not eligible exposure. [pmid: 12478671].
417 Sharp GB, Mizuno T, Fukuhara T, Tokuoka S, Sharp GB, Mizuno T, et al. Lack of association between acute exposure to ionizing radiation and liver cirrhosis. Int J Radiat Biol. Apr. 2006;82(4):231-40. Not eligible exposure. [pmid: 16690591].
418 Sheen IS, Liaw YF, Lin DY, Chu CM, Sheen IS, Liaw YF, et al. Acute exacerbations in chronic hepatitis C: a clinicopathological and prognostic study. Journal of Hepatology. May. 1996;24(5):525-31. Not eligible exposure. [pmid: 8773906].
419 Shen F, Huang Q, Sun HQ, Ghildyal R, Shen F, Huang Q, et al. Significance of blood analysis in hemophiliacs co-infected with human immunodeficiency virus and hepatitis viruses. World J Gastroenterol. Mar 28. 2007;13(12):1862-6. Not relevant outcomes. [pmid: 17465482].
420 Sheng WH, Hung CC, Kao JH, Chang SY, Chen MY, Hsieh SM, et al. Impact of hepatitis D virus infection on the long-term outcomes of patients with hepatitis B virus and HIV coinfection in the era of highly active antiretroviral therapy: a matched cohort study. Clin Infect Dis. Apr 1. 2007;44(7):988-95. Not eligible exposure. [pmid: 17342655].
421 Shepherd J, Jones J, Takeda A, Davidson P, Price A, Shepherd J, et al. Adefovir dipivoxil and pegylated interferon alfa-2a for the treatment of chronic hepatitis B: a systematic review and economic evaluation. Health Technology Assessment (Winchester, England) 2006 2006 Aug;10(28):iii–iv, 1–183. Review
422 Sherlock S, Sherlock S. Immunosuppressive therapy in chronic liver disease. Minerva Med. Aug 18. 1978;69(38):2605-9. Review. [pmid: 714260].
423 Sherman M, Shafritz DA, Sherman M, Shafritz DA. Hepatitis B virus and hepatocellular carcinoma: molecular biology and mechanistic considerations. Semin Liver Dis. May. 1984;4(2):98-112. Review. [pmid: 6087462].
424 Shin HD, Park BL, Cheong HS, Yoon JH, Kim YJ, Lee HS. SPP1 polymorphisms associated with HBV clearance and HCC occurrence. International Journal of Epidemiology. Oct. 2007;36(5):1001-8. Not eligible exposure. [pmid: 17496055].
425 Shin HD, Park BL, Kim LH, Jung JH, Kim JY, Yoon JH, et al. Interleukin 10 haplotype associated with increased risk of hepatocellular carcinoma. Hum Mol Genet. Apr 15. 2003;12(8):901-6. Review. [pmid: 12668613].
426 Shuqun C, Mengchao W, Han C, Feng S, Jiahe Y, Wenming C, et al. Antiviral therapy using lamivudine and thymosin alpha1 for hepatocellular carcinoma coexisting with chronic hepatitis B infection. Hepato-Gastroenterology. Mar–Apr. 2006;53(68):249-52. Less than 1000 patients and not US study. [pmid: 16608033].
427 Siciliano M, Barbesino G, Marra L, Milani A, Rossi L, Siciliano M, et al. Long-term prognostic value of serum bile acids in liver cirrhosis: a prospective study. Z Gastroenterol. Nov. 1989;27(11):653-6. Not eligible exposure. [pmid: 2575828].
428 Silva AE, Hosein B, Boyle RW, Fang CT, Shindo M, Waggoner JG, et al. Diagnosis of chronic hepatitis C: comparison of immunoassays and the polymerase chain reaction. American Journal of Gastroenterology. Apr. 1994;89(4):493-6. Not eligible exposure. [pmid: 8147348].
429 Sjogren MH, Lemon SM, Chung WK, Sun HS, Hoofnagle JH, Sjogren MH, et al. IgM antibody to hepatitis B core antigen in Korean patients with hepatocellular carcinoma. Hepatology. Jul–Aug. 1984;4(4):615-8. Not relevant outcomes. [pmid: 6204916].
430 Sloan EP, McGill BA, Zalenski R, Tsui P, Chen EH, Duda J, et al. Human immunodeficiency virus and hepatitis B virus seroprevalence in an urban trauma population. J Trauma. May. 1995;38(5):736-41. Not relevant outcomes. [pmid: 7760401].
431 Smith HM, Alexander GJ, Webb G, McManus T, McFarlane IG, Williams R, et al. Hepatitis B and delta virus infection among “at risk” populations in south east London. J Epidemiol Community Health. Apr. 1992;46(2):144-7. Not relevant outcomes. [pmid: 1583429].
432 Solinas A, Madeddu G, Tocco A, Deplano A, Diana MS, Pirisi M, et al. Alpha-fetoprotein and hepatitis B virus infection in chronic liver disease. J Nucl Med Allied Sci. Apr–Jun. 1987;31(2):183-8. Not relevant outcomes. [pmid: 2442327].
433 Solomon L, Flynn C, Lavetsky G, Solomon L, Flynn C, Lavetsky G. Managed care for AIDS patients: is bigger better?. Journal of Acquired Immune Deficiency Syndromes: JAIDS. Mar 1. 2005;38(3):342-7. Not eligible exposure.
434 Spadaro A, Luigiano C, De Caro G, Morace C, Tortorella V, Bonfiglio C, et al. Prognostic factors of survival in complicated viral and alcoholic cirrhosis without hepatocellular carcinoma. A retrospective study. Minerva Gastroenterologica e Dietologica. Dec. 2007;53(4):311-9. Less than 1000 patients and not US study. [pmid: 18043549].
435 Squadrito G, Pollicino T, Cacciola I, Caccamo G, Villari D, La Masa T, et al. Occult hepatitis B virus infection is associated with the development of hepatocellular carcinoma in chronic hepatitis C patients. Cancer. Mar 15. 2006;106(6):1326-30. Less than 1000 patients and not US study. [pmid: 16453330].
436 Sterneck M, Gunther S, Gerlach J, Naoumov NV, Santantonio T, Fischer L, et al. Hepatitis B virus sequence changes evolving in liver transplant recipients with fulminant hepatitis. Journal of Hepatology. Apr. 1997;26(4):754-64. Not eligible exposure. [pmid: 9126786].
437 Stroffolini T, Almasio PL, Di Stefano R, Andreone P, Di Gaetano G, Fattovich G, et al. Anti-hepatitis A virus seroprevalence and seroconversion in a cohort of patients with chronic viral hepatitis. Dig Liver Dis. Sep. 2002;34(9):656-9. Not eligible exposure. [pmid: 12405253].
438 Stroffolini T, Stroffolini T. Etiological factor of hepatocellular carcinoma in Italy. Minerva Gastroenterologica e Dietologica. Mar. 2005;51(1):1-5. Review. [pmid: 15756142].
439 Su CW, Huang YH, Huo TI, Shih HH, Sheen IJ, Chen SW, et al. Genotypes and viremia of hepatitis B and D viruses are associated with outcomes of chronic hepatitis D patients. Gastroenterology. May. 2006;130(6):1625-35. Not eligible target population. [pmid: 16697726].
440 Su WP, Wen CC, Hsiung CA, Su IJ, Cheng AL, Chang MC, et al. Long-term hepatic consequences of chemotherapy-related HBV reactivation in lymphoma patients. World J Gastroenterol. Sep 14. 2005;11(34):5283-8. Not relevant outcomes. [pmid: 16149133].
441 Sullivan PS, Hanson DL, Teshale EH, Wotring LL, Brooks JT, Sullivan PS, et al. Effect of hepatitis C infection on progression of HIV disease and early response to initial antiretroviral therapy. AIDS. May 12. 2006;20(8):1171-9. Not eligible exposure. [pmid: 16691069].
442 Sun CA, Wu DM, Lin CC, Lu SN, You SL, Wang LY, et al. Incidence and cofactors of hepatitis C virus-related hepatocellular carcinoma: a prospective study of 12,008 men in Taiwan. Am J Epidemiol. Apr 15. 2003;157(8):674-82. Not eligible exposure. [pmid: 12697571].
443 Sun HC, Zhang W, Qin LX, Zhang BH, Ye QH, Wang L, et al. Positive serum hepatitis B e antigen is associated with higher risk of early recurrence and poorer survival in patients after curative resection of hepatitis B-related hepatocellular carcinoma. Journal of Hepatology. Nov. 2007;47(5):684-90. Less than 1000 patients and not US study. [pmid: 17854945].
444 Sun Z, Lu P, Gail MH, Pee D, Zhang Q, Ming L, et al. Increased risk of hepatocellular carcinoma in male hepatitis B surface antigen carriers with chronic hepatitis who have detectable urinary aflatoxin metabolite M1. Hepatology. Aug. 1999;30(2):379-83. Less than 1000 patients and not US study. [pmid: 10421643].
445 Sundaravalli N, Nedunchezian Sankaranarayanan VS, Sriramachari S, Iyengar B, Nayak NC, et al. HBs antigenemia in chronic liver disorders in infancy and childhood. Trop Gastroenterol. Apr–Jun. 1988;9(2):80-2. Not eligible target population. [pmid: 3176165].
446 Sung JJ, Tsui SK, Tse CH, Ng EY, Leung KS, Lee KH, et al. Genotype-specific genomic markers associated with primary hepatomas, based on complete genomic sequencing of hepatitis B virus. Journal of Virology. Apr. 2008;82(7):3604-11. Less than 1000 patients and not US study. [pmid: 18216102].
447 Syed NA, Hearing SD, Shaw IS, Probert CS, Brooklyn TN, Caul EO, et al. Outbreak of hepatitis A in the injecting drug user and homeless populations in Bristol: control by a targeted vaccination programme and possible parenteral transmission. Eur J Gastroenterol Hepatol. Aug. 2003;15(8):901-6. Not eligible exposure. [pmid: 12867801].
448 Tai DI, Lo SK, Kuo CH, Du JM, Chen CJ, Hung CS, et al. Replication of hepatitis B in HBsAg-positive siblings. Journal of Viral Hepatitis. Jul. 2002;9(4):272-9. Not relevant outcomes. [pmid: 12081604].
449 Takahashi Y, Kumada H, Shimizu M, Tanikawa K, Kumashiro R, Omata M, et al. A multicenter study on the prognosis of fulminant viral hepatitis: early prediction for liver transplantation. Hepatology. May. 1994;19(5):1065-71. Not relevant outcomes. [pmid: 8175127].
450 Takano S, Yokosuka O, Imazeki F, Tagawa M, Omata M, Takano S, et al. Incidence of hepatocellular carcinoma in chronic hepatitis B and C: a prospective study of 251 patients. Hepatology. Mar. 1995;21(3):650-5. Less than 1000 patients and not US study. [pmid: 7875662].
451 Tam TN, Ng WW, Lee SD, Tam TN, Ng WW, Lee SD. Colonic mucosal changes in patients with liver cirrhosis. Gastrointest Endosc. Nov. 1995;42(5):408-12. Not relevant outcomes. [pmid: 8566628].
452 Tandon BN, Joshi YK, Krishnamurthy L, Tandon HD, Tandon BN, Joshi YK, et al. Subacute hepatic failure; is it a distinct entity?. J Clin Gastroenterol 1982. Aug. 1982;4(4):343-6. Not relevant outcomes.
453 Tang B, Kruger WD, Chen G, Shen F, Lin WY, Mboup S, et al. Hepatitis B viremia is associated with increased risk of hepatocellular carcinoma in chronic carriers. Journal of Medical Virology. Jan. 2004;72(1):35-40. Less than 1000 patients and not US study. [pmid: 14635008].
454 Targhetta S, Villamil F, Inturri P, Pontisso P, Fagiuoli S, Cillo U, et al. Protocol liver biopsies in long-term management of patients transplanted for hepatitis B-related liver disease. World J Gastroenterol. Mar 21. 2006;12(11):1706-12. Not relevant outcomes. [pmid: 16586538].
455 Tassopoulos NC, Koutelou MG, Macagno S, Zorbas P, Rizzetto M, Tassopoulos NC, et al. Diagnostic significance of IgM antibody to hepatitis delta virus in fulminant hepatitis B. Journal of Medical Virology. Mar. 1990;30(3):174-7. Not relevant outcomes. [pmid: 2341833].
456 Tatulli I, Francavilla R, Rizzo GL, Vinciguerra V, Ierardi E, Amoruso A, et al. Lamivudine and alpha-interferon in combination long term for precore mutant chronic hepatitis B. Journal of Hepatology. Dec. 2001;35(6):805-10. Not relevant outcomes. [pmid: 11738109].
457 Taura N, Hamasaki K, Nakao K, Ichikawa T, Nishimura D, Goto T, et al. Aging of patients with hepatitis C virus-associated hepatocellular carcinoma: long-term trends in Japan. Oncol Rep. Oct. 2006;16(4):837-43. Not eligible exposure. [pmid: 16969503].
458 Tchervenkov JI, Tector AJ, Barkun JS, Sherker A, Forbes CD, Elias N, et al. Recurrence-free long-term survival after liver transplantation for hepatitis B using interferon-alpha pretransplant and hepatitis B immune globulin posttransplant. Ann Surg. Sep. 1997;226(3):356-65. discussion 65–8. Not relevant outcomes. [pmid: 9339942].
459 Tchou JC, Lin X, Freije D, Isaacs WB, Brooks JD, Rashid A, et al. GSTP1 CpG island DNA hypermethylation in hepatocellular carcinomas. Int J Oncol. Apr. 2000;16(4):663-76. Not relevant outcomes. [pmid: 10717233].
460 Teo EK, Han SH, Terrault N, Luketic V, Jensen D, Keeffe EB, et al. Liver transplantation in patients with hepatitis B virus infection: outcome in Asian versus white patients. Hepatology. Jul. 2001;34(1):126-32. Not relevant outcomes. [pmid: 11431743].
461 Teo EK, Ostapowicz G, Hussain M, Lee WM, Fontana RJ, Lok AS, et al. Hepatitis B infection in patients with acute liver failure in the United States. Hepatology. Apr. 2001;33(4):972-6. Not relevant outcomes. [pmid: 11283862].
462 Thakur V, Guptan RC, Kazim SN, Malhotra V, Sarin SK, Thakur V, et al. Profile, spectrum and significance of HBV genotypes in chronic liver disease patients in the Indian subcontinent. Journal of Gastroenterology & Hepatology. Feb. 2002;17(2):165-70. Less than 1000 patients and not US study. [pmid: 11966946].
463 Thompson Coon J, Rogers G, Hewson P, Wright D, Anderson R, Cramp M, et al. Surveillance of cirrhosis for hepatocellular carcinoma: systematic review and economic analysis. Health Technology Assessment (Winchester, England). Sep. 2007;11(34):1-206. Review.
464 Tien PC, Kovacs A, Bacchetti P, French AL, Augenbraun M, Cole SR, et al. Association between syphilis, antibodies to herpes simplex virus type 2, and recreational drug use and hepatitis B virus infection in the Women's Interagency HIV Study. Clin Infect Dis. Nov 1. 2004;39(9):1363-70. Not relevant outcomes. [pmid: 15494914].
465 Tine F, Liberati A, Craxi A, Almasio P, Pagliaro L, Tine F, et al. Interferon treatment in patients with chronic hepatitis B: a meta-analysis of the published literature. Journal of Hepatology. Jun. 1993;18(2):154-62. Review. [pmid: 7691924].
466 Toan NL, Song le H, Kremsner PG, Duy DN, Binh VQ, Koeberlein B, et al. Impact of the hepatitis B virus genotype and genotype mixtures on the course of liver disease in Vietnam. Hepatology. Jun. 2006;43(6):1375-84. Not relevant outcomes. [pmid: 16729315].
467 Torres-Baranda R, Bastidas-Ramirez BE, Maldonado-Gonzalez M, Sanchez-Orozco LV, Vazquez-Vals E, Rodriguez-Noriega E, et al. Occult hepatitis B in Mexican patients with HIV, an analysis using nested polymerase chain reaction. Ann Hepatol. Jan–Mar. 2006;5(1):34-40. Not relevant outcomes. [pmid: 16531963].
468 Tourret J, Tostivint I, du Montcel ST, Bragg-Gresham J, Karie S, Vigneau C, et al. Outcome and prognosis factors in HIV-infected hemodialysis patients. Clin J Am Soc Nephrol. Nov. 2006;1(6):1241-7. Not eligible exposure. [pmid: 17699354].
469 Toyoda H, Kumada T, Kaneoka Y, Murakami Y. Impact of hepatitis B virus (HBV) X gene integration in liver tissue on hepatocellular carcinoma development in serologically HBV-negative chronic hepatitis C patients. Journal of Hepatology. Jan. 2008;48(1):43-50. Not eligible exposure. [pmid: 18023912].
470 Trevisani F, Caraceni P, Bernardi M, D'Intino PE, Arienti V, Amorati P, et al. Gross pathologic types of hepatocellular carcinoma in Italian patients. Relationship with demographic, environmental, and clinical factors. Cancer. Sep 1. 1993;72(5):1557-63. Not relevant outcomes. [pmid: 8394197].
471 Trevisani F, D'Intino PE, Caraceni P, Pizzo M, Stefanini GF, Mazziotti A, et al. Etiologic factors and clinical presentation of hepatocellular carcinoma. Differences between cirrhotic and noncirrhotic Italian patients. Cancer. May 1. 1995;75(9):2220-32. Not relevant outcomes. [pmid: 7536121].
472 Trevisani F, Magini G, Santi V, Morselli-Labate AM, Cantarini MC, Di Nolfo MA, et al. Impact of etiology of cirrhosis on the survival of patients diagnosed with hepatocellular carcinoma during surveillance. American Journal of Gastroenterology. May. 2007;102(5):1022-31. Not eligible target population. [pmid: 17313497].
473 Tsai JF, Jeng JE, Ho MS, Chang WY, Hsieh MY, Lin ZY, et al. Effect of hepatitis C and B virus infection on risk of hepatocellular carcinoma: a prospective study. Br J Cancer. 1997;76(7):968-74. Less than 1000 patients and not US study. [pmid: 9328161].
474 Tsega E, Hansson BG, Krawczynski K, Nordenfelt E, Tsega E, Hansson BG, et al. Acute sporadic viral hepatitis in Ethiopia: causes, risk factors, and effects on pregnancy. Clin Infect Dis. Apr. 1992;14(4):961-5. Not relevant outcomes. [pmid: 1576296].
475 Tsega E, Nordenfelt E, Hansson BG, Mengesha B, Lindberg J, Tsega E, et al. Chronic liver disease in Ethiopia: a clinical study with emphasis on identifying common causes. Ethiop Med J. Apr. 1992;30(2 Suppl):1-33. Not relevant outcomes. [pmid: 1319901].
476 Tsochatzis E, Papatheodoridis GV, Manesis EK, Kafiri G, Tiniakos DG, Archimandritis AJ. Metabolic syndrome is associated with severe fibrosis in chronic viral hepatitis and non-alcoholic steatohepatitis. Alimentary Pharmacology & Therapeutics. Jan 1. 2008;27(1):80-9. Not relevant outcomes. [pmid: 17919273].
477 Tsubota A, Arase Y, Ren F, Tanaka H, Ikeda K, Kumada H, et al. Genotype may correlate with liver carcinogenesis and tumor characteristics in cirrhotic patients infected with hepatitis B virus subtype adw. Journal of Medical Virology. Oct. 2001;65(2):257-65. Less than 1000 patients and not US study. [pmid: 11536231].
478 Tsubota A, Arase Y, Suzuki Y, Suzuki F, Hosaka T, Akuta N, et al. Benefit of lamivudine therapy and factors associated with clinical outcome in spontaneous severe acute exacerbation of chronic hepatitis B virus infection. Intervirology. Nov–Dec. 2004;47(6):335-41. Less than 1000 patients and not US study. [pmid: 15564745].
479 Uchimura S, Iizuka N, Tamesa T, Miyamoto T, Hamamoto Y, Oka M. Resampling based on geographic patterns of hepatitis virus infection reveals a common gene signature for early intrahepatic recurrence of hepatocellular carcinoma. Anticancer Research. Sep–Oct. 2007;27(5A):3323-30. Not relevant outcomes. [pmid: 17970077].
480 Ueno Y, Moriyama M, Uchida T, Arakawa Y, Ueno Y, Moriyama M, et al. Irregular regeneration of hepatocytes is an important factor in the hepatocarcinogenesis of liver disease. Hepatology. Feb. 2001;33(2):357-62. Not relevant outcomes. [pmid: 11172337].
481 Uetake S, Yamauchi M, Itoh S, Kawashima O, Takeda K, Ohata M, et al. Analysis of risk factors for hepatocellular carcinoma in patients with HBs antigen- and anti-HCV antibody-negative alcoholic cirrhosis: clinical significance of prior hepatitis B virus infection. Alcohol Clin Exp Res. Aug. 2003;27(8 Suppl):47S-51S. Less than 1000 patients and not US study. [pmid: 12960507].
482 Ulcickas Yood M, Quesenberry CP Jr, Guo D, Caldwell C, Wells K, Shan J, et al. Incidence of non-Hodgkin's lymphoma among individuals with chronic hepatitis B virus infection. Hepatology. Jul. 2007;46(1):107-12. Not relevant outcomes. [pmid: 17526021].
483 Utili R, Zampino R, Bellopede P, Marracino M, Ragone E, Adinolfi LE, et al. Dual or single hepatitis B and C virus infections in childhood cancer survivors: long-term follow-up and effect of interferon treatment. Blood. Dec 15. 1999;94(12):4046-52. Not relevant outcomes. [pmid: 10590048].
484 van der Poorten D, Prakoso E, Khoo TL, Ngu MC, McCaughan GW, Strasser SI, et al. Combination adefovir-lamivudine prevents emergence of adefovir resistance in lamivudine-resistant hepatitis B. Journal of Gastroenterology & Hepatology. Sep. 2007;22(9):1500-5. Not relevant outcomes. [pmid: 17683493].
485 Van Herck K, Leroux-Roels G, Van Damme P, Srinivasa K, Hoet B, Van Herck K, et al. Ten-year antibody persistence induced by hepatitis A and B vaccine (Twinrix) in adults. Travel Med Infect Dis. May. 2007;5(3):171-5. Not eligible exposure. [pmid: 17448944].
486 van Zonneveld M, Honkoop P, Hansen BE, Niesters HG, Murad SD, de Man RA, et al. Long-term follow-up of alpha-interferon treatment of patients with chronic hepatitis B. Hepatology. Mar. 2004;39(3):804-10. Less than 1000 patients and not US study. [pmid: 14999700].
487 Vento S, Garofano T, Renzini C, Cainelli F, Casali F, Ghironzi G, et al. Fulminant hepatitis associated with hepatitis A virus superinfection in patients with chronic hepatitis C. N Engl J Med. Jan 29. 1998;338(5):286-90. Not relevant outcomes. [pmid: 9445408].
488 Vigano M, Colombo M, Aroldi A, Lunghi G, Manenti E, Ponticelli C, et al. Long-term lamivudine monotherapy in renal-transplant recipients with hepatitis-B-related cirrhosis. Antiviral Therapy. 2005;10(6):709-13. Not eligible target population. [pmid: 16218169].
489 Villa E, Grottola A, Buttafoco P, Trande P, Merighi A, Fratti N, et al. Evidence for hepatitis B virus infection in patients with chronic hepatitis C with and without serological markers of hepatitis B. Dig Dis Sci. Jan. 1995;40(1):8-13. Less than 1000 patients and not US study. [pmid: 7529674].
490 Villeneuve JP, Desrochers M, Infante-Rivard C, Willems B, Raymond G, Bourcier M, et al. A long-term follow-up study of asymptomatic hepatitis B surface antigen-positive carriers in Montreal. Gastroenterology. Apr. 1994;106(4):1000-5. Less than 1000 patients and not US study. [pmid: 8143967].
491 Wai CT, Fontana RJ, Polson J, Hussain M, Shakil AO, Han SH, et al. Clinical outcome and virological characteristics of hepatitis B-related acute liver failure in the United States. Journal of Viral Hepatitis. Mar. 2005;12(2):192-8. Not relevant outcomes. [pmid: 15720535].
492 Wang FS, Wang FS. Current status and prospects of studies on human genetic alleles associated with hepatitis B virus infection. World J Gastroenterol. Apr. 2003;9(4):641-4. Review. [pmid: 12679901].
493 Wang JN, Chen JS, Chuang HY, Yang YJ, Chang KC, Wu JM, et al. Invasion of the cardiovascular system in childhood malignant hepatic tumors. J Pediatr Hematol Oncol. Aug–Sep. 2002;24(6):436-9. Not eligible target population. [pmid: 12218589].
494 Wang JS, Qian GS, Zarba A, He X, Zhu YR, Zhang BC, et al. Temporal patterns of aflatoxin-albumin adducts in hepatitis B surface antigen-positive and antigen-negative residents of Daxin, Qidong County, People's Republic of China. Cancer Epidemiol Biomarkers Prev. Apr. 1996;5(4):253-61. Not relevant outcomes. [pmid: 8722216].
495 Wang LY, Hatch M, Chen CJ, Levin B, You SL, Lu SN, et al. Aflatoxin exposure and risk of hepatocellular carcinoma in Taiwan. Int J Cancer. Sep 4. 1996;67(5):620-5. Not relevant outcomes. [pmid: 8782648].
496 Wang SS, Tsai YT, Lee SD, Chen HT, Lu CW, Lee FY, et al. Spontaneous bacterial peritonitis in patients with hepatitis B-related cirrhosis and hepatocellular carcinoma. Gastroenterology. Dec. 1991;101(6):1656-62. Less than 1000 patients and not US study. [pmid: 1659549].
497 Wang YJ, Lee SD, Hsieh MC, Lin HC, Lee FY, Tsay SH, et al. A double-blind randomized controlled trial of colchicine in patients with hepatitis B virus-related postnecrotic cirrhosis. Journal of Hepatology. Nov. 1994;21(5):872-7. Less than 1000 patients and not US study. [pmid: 7890905].
498 Wang Z, Hou J, Zeng G, Wen S, Tanaka Y, Cheng J, et al. Distribution and characteristics of hepatitis B virus genotype C subgenotypes in China. Journal of Viral Hepatitis. Jun. 2007;14(6):426-34. Not relevant outcomes. [pmid: 17501764].
499 Wang Z, Tanaka Y, Huang Y, Kurbanov F, Chen J, Zeng G, et al. Clinical and virological characteristics of hepatitis B virus subgenotypes Ba, C1, and C2 in China. J Clin Microbiol. May. 2007;45(5):1491-6. Not relevant outcomes. [pmid: 17376881].
500 Welzel TM, Katki HA, Sakoda LC, Evans AA, London WT, Chen G, et al. Blood folate levels and risk of liver damage and hepatocellular carcinoma in a prospective high-risk cohort. Cancer Epidemiol Biomarkers Prev. Jun. 2007;16(6):1279-82. Less than 1000 patients and not US study. [pmid: 17548697].
501 Wen WH, Chang MH, Hsu HY, Ni YH, Chen HL, Wen WH, et al. The development of hepatocellular carcinoma among prospectively followed children with chronic hepatitis B virus infection. J Pediatr. Mar. 2004;144(3):397-9. Not eligible target population. [pmid: 15001956].
502 Weng HL, Wang BE, Jia JD, Wu WF, Xian JZ, Mertens PR, et al. Effect of interferon-gamma on hepatic fibrosis in chronic hepatitis B virus infection: a randomized controlled study. Clinical Gastroenterology & Hepatology. Aug. 2005;3(8):819-28. Not eligible target population. [pmid: 16234012].
503 Whelchel JD, Pass RF, Diethelm AG, Whitley RJ, Alford CA Jr, Whelchel JD, et al. Effect of primary and recurrent cytomegalovirus infections upon graft and patient survival after renal transplantation. Transplantation. Dec. 1979;28(6):443-6. Not eligible exposure. [pmid: 229592].
504 Wiedmann M, Liebert UG, Oesen U, Porst H, Wiese M, Schroeder S, et al. Decreased immunogenicity of recombinant hepatitis B vaccine in chronic hepatitis C. Hepatology. Jan. 2000;31(1):230-4. Not eligible exposure. [pmid: 10613751].
505 Wild CP, Turner PC, Wild CP, Turner PC. The toxicology of aflatoxins as a basis for public health decisions. Mutagenesis. Nov. 2002;17(6):471-81. Not eligible exposure. [pmid: 12435844].
506 Wilmer A, Nolchen B, Tilg H, Herold M, Pechlaner C, Judmaier G, et al. Serum neopterin concentrations in chronic liver disease. Gut. Jul. 1995;37(1):108-12. Not eligible exposure. [pmid: 7672657].
507 Wilson JN, Nokes DJ, Carman WF, Wilson JN, Nokes DJ, Carman WF. Predictions of the emergence of vaccine-resistant hepatitis B in The Gambia using a mathematical model. Epidemiol Infect. Apr. 2000;124(2):295-307. Not relevant outcomes. [pmid: 10813156].
508 Wolters LM, Niesters HG, Hansen BE, van der Ende ME, Kroon FP, Richter C, et al. Development of hepatitis B virus resistance for lamivudine in chronic hepatitis B patients co-infected with the human immunodeficiency virus in a Dutch cohort. J Clin Virol. Apr. 2002;24(3):173-81. Not relevant outcomes. [pmid: 11856618].
509 Wong GC, Tan P, Goh YT, Ng HS, Chong R, Lee LH, et al. Exacerbation of hepatitis in hepatitis B carriers following chemotherapy for haematological malignancies. Ann Acad Med Singapore. Jul. 1996;25(4):500-3. Not relevant outcomes. [pmid: 8893918].
510 Wong JB, Wong JB. Interferon treatment for chronic hepatitis B or C infection: costs and effectiveness. Acta Gastroenterol Belg. Apr–Jun. 1998;61(2):238-42. Not relevant outcomes. [pmid: 9658620].
511 Woodruff AW, Adamson EA, el Suni A, Maughan TS, Kaku M, Bundru W, et al. Children in Juba, southern Sudan: the second and third years of life. Lancet. Sep 13. 1986;2(8507):615-8. Not eligible target population. [pmid: 2875327].
512 Worns MA, Teufel A, Kanzler S, Shrestha A, Victor A, Otto G, et al. Incidence of HAV and HBV infections and vaccination rates in patients with autoimmune liver diseases. American Journal of Gastroenterology. Jan. 2008;103(1):138-46. Not relevant outcomes. [pmid: 17970833].
513 Wu CC, Tang JS, Lin MC, Yeh DC, Liu TJ, P'Eng FK, et al. Comparison of liver resection for hepatocellular carcinoma in hepatitis B and hepatitis C-related cirrhotic patients. Hepato-Gastroenterology. Mar–Apr. 1999;46(26):651-5. Not relevant outcomes. [pmid: 10370591].
514 Wu GC, Zhou WP, Zhao YR, Guo SH, Wang ZY, Zou SB, et al. The natural history of chronic hepatitis B: a retrospective study. Hepatobiliary Pancreat Dis Int. Nov. 2003;2(4):566-70. Less than 1000 patients and not US study. [pmid: 14627521].
515 Wu HC, Wang Q, Wang LW, Yang HI, Ahsan H, Tsai WY, et al. Polycyclic aromatic hydrocarbon- and aflatoxin-albumin adducts, hepatitis B virus infection and hepatocellular carcinoma in Taiwan. Cancer Lett. Jul 8. 2007;252(1):104-14. Not relevant outcomes. [pmid: 17250958].
516 Wu HC, Wang Q, Wang LW, Yang HI, Ahsan H, Tsai WY, et al. Urinary 8-oxodeoxyguanosine, aflatoxin B1 exposure and hepatitis B virus infection and hepatocellular carcinoma in Taiwan. Carcinogenesis. May. 2007;28(5):995-9. Not relevant outcomes. [pmid: 17127712].
517 Xu B, Hu DC, Rosenberg DM, Jiang QW, Lin XM, Lu JL, et al. Chronic hepatitis B: a long-term retrospective cohort study of disease progression in Shanghai, China. Journal of Gastroenterology & Hepatology. Dec. 2003;18(12):1345-52. Less than 1000 patients and not US study. [pmid: 14675261].
518 Xunrong L, Yan AW, Liang R, Lau GK, Xunrong L, Yan AW, et al. Hepatitis B virus (HBV) reactivation after cytotoxic or immunosuppressive therapy—pathogenesis and management. Rev Med Virol. Sep–Oct. 2001;11(5):287-99. Review. [pmid: 11590667].
519 Yaci M, Acar K, Sucak GT, Aki Z, Bozdayi G, Haznedar R, et al. A prospective study on chemotherapy-induced hepatitis B virus reactivation in chronic HBs Ag carriers with hematologic malignancies and pre-emptive therapy with nucleoside analogues. Leuk Lymphoma. Aug. 2006;47(8):1608-12. Not relevant outcomes. [pmid: 16966273].
520 Yaci M, Acar K, Sucak GT, Aki Z, Bozdayi G, Haznedar R, et al. A prospective study on chemotherapy-induced hepatitis B virus reactivation in chronic HBs Ag carriers with hematologic malignancies and pre-emptive therapy with nucleoside analogues.[erratum appears in Leuk Lymphoma. 2006 Dec;47(12):2676 Note: Yaci, Muncy [corrected to Yaci, Munci]; Acar, Kadyr [corrected to Acar, Kadir]]. Leuk Lymphoma. Aug. 2006;47(8):1608-12. Not relevant outcomes. [pmid: 16966273].
521 Yaghi C, Sharara AI, Rassam P, Moucari R, Honein K, BouJaoude J, et al. Hepatocellular carcinoma in Lebanon: Etiology and prognostic factors associated with short-term survival. World J Gastroenterol. Jun 14. 2006;12(22):3575-80. Less than 1000 patients and not US study. [pmid: 16773714].
522 Yalcin K, Deertekin H, Alp MN, Teke S, Satici O, Budak T, et al. Determination of serum hepatitis B virus DNA in chronic HBsAg carriers: clinical significance and correlation with serological markers. Turk J Gastroenterol. Sep. 2003;14(3):157-63. Not relevant outcomes. [pmid: 14655057].
523 Yang CH, Wu TS, Chiu CT. Chronic hepatitis B reactivation: a word of caution regarding the use of systemic glucocorticosteroid therapy. British Journal of Dermatology. Sep. 2007;157(3):587-90. Not relevant outcomes. [pmid: 17596145].
524 Yao FY, Terrault NA, Freise C, Maslow L, Bass NM, Yao FY, et al. Lamivudine treatment is beneficial in patients with severely decompensated cirrhosis and actively replicating hepatitis B infection awaiting liver transplantation: a comparative study using a matched, untreated cohort. Hepatology. Aug. 2001;34(2):411-6. Not relevant outcomes. [pmid: 11481627].
525 Yeh FS, Yu MC, Mo CC, Luo S, Tong MJ, Henderson BE, et al. Hepatitis B virus, aflatoxins, and hepatocellular carcinoma in southern Guangxi, China. Cancer Res. May 1. 1989;49(9):2506-9. Not relevant outcomes. [pmid: 2539905].
526 Yeh WC, Yang PM, Huang GT, Sheu JC, Chen DS, Yeh WC, et al. Long-term follow-up of hepatic hemangiomas by ultrasonography: with emphasis on the growth rate of the tumor. Hepato-Gastroenterology. Mar. 2007;54(74):475-9. Not eligible exposure. [pmid: 17523302].
527 Yen-Xuan NT, Dieu-Hien PT, Nga CN, Croce LS, Yen-Xuan NT, Dieu-Hien PT, et al. Clinical and virological features of acute HBV-related hepatitis in southern Vietnam. Ann Hepatol. Apr–Jun. 2006;5(2):92-6. Not relevant outcomes. [pmid: 16821281].
528 Yeo W, Chan PK, Zhong S, Ho WM, Steinberg JL, Tam JS, et al. Frequency of hepatitis B virus reactivation in cancer patients undergoing cytotoxic chemotherapy: a prospective study of 626 patients with identification of risk factors. Journal of Medical Virology. Nov. 2000;62(3):299-307. Not relevant outcomes. [pmid: 11055239].
529 Yeo W, Lam KC, Zee B, Chan PS, Mo FK, Ho WM, et al. Hepatitis B reactivation in patients with hepatocellular carcinoma undergoing systemic chemotherapy. Ann Oncol. Nov. 2004;15(11):1661-6. Not relevant outcomes. [pmid: 15520068].
530 Yeo W, Mo FK, Chan SL, Leung NW, Hui P, Lam WY, et al. Hepatitis B viral load predicts survival of HCC patients undergoing systemic chemotherapy. Hepatology. Jun. 2007;45(6):1382-9. Not relevant outcomes. [pmid: 17539025].
531 Yood MU, Quesenberry CP Jr, Guo D, Wells K, Shan J, Sanders L, et al. Incidence of hepatocellular carcinoma among individuals with hepatitis B virus infection identified using an automated data algorithm. Journal of Viral Hepatitis. Jan. 2008;15(1):28-36. Not relevant outcomes. [pmid: 18088242].
532 Yoshiba M, Inoue K, Sekiyama K, Koh I, Yoshiba M, Inoue K, et al. Favorable effect of new artificial liver support on survival of patients with fulminant hepatic failure. Artif Organs. Nov. 1996;20(11):1169-72. Not relevant outcomes. [pmid: 8908326].
533 You SL, Yang HI, Chen CJ, You SL, Yang HI, Chen CJ. Seropositivity of hepatitis B e antigen and hepatocellular carcinoma. Ann Med. 2004;36(3):215-24. Review. [pmid: 15181977].
534 Yu MW, Chang HC, Chen PJ, Liu CJ, Liaw YF, Lin SM, et al. Increased risk for hepatitis B-related liver cirrhosis in relatives of patients with hepatocellular carcinoma in northern Taiwan. International Journal of Epidemiology. Oct. 2002;31(5):1008-15. Not relevant outcomes. [pmid: 12435776].
535 Yu MW, Chang HC, Liaw YF, Lin SM, Lee SD, Liu CJ, et al. Familial risk of hepatocellular carcinoma among chronic hepatitis B carriers and their relatives. J Natl Cancer Inst. Jul 19. 2000;92(14):1159-64. Not relevant outcomes. [pmid: 10904089].
536 Yu MW, Chen CJ, Luo JC, Brandt-Rauf PW, Carney WP, Santella RM, et al. Correlations of chronic hepatitis B virus infection and cigarette smoking with elevated expression of neu oncoprotein in the development of hepatocellular carcinoma. Cancer Res. Oct 1. 1994;54(19):5106-10. Not relevant outcomes. [pmid: 7923126].
537 Yu MW, Cheng SW, Lin MW, Yang SY, Liaw YF, Chang HC, et al. Androgen-receptor gene CAG repeats, plasma testosterone levels, and risk of hepatitis B-related hepatocellular carcinoma. J Natl Cancer Inst. Dec 20. 2000;92(24):2023-8. Not relevant outcomes. [pmid: 11121465].
538 Yu MW, Chiu YH, Yang SY, Santella RM, Chern HD, Liaw YF, et al. Cytochrome P450 1A1 genetic polymorphisms and risk of hepatocellular carcinoma among chronic hepatitis B carriers. Br J Cancer. May. 1999;80(34):598-603. Not relevant outcomes. [pmid: 10408872].
539 Yu MW, Horng IS, Hsu KH, Chiang YC, Liaw YF, Chen CJ, et al. Plasma selenium levels and risk of hepatocellular carcinoma among men with chronic hepatitis virus infection. Am J Epidemiol. Aug 15. 1999;150(4):367-74. Not relevant outcomes. [pmid: 10453813].
540 Yu MW, Hsieh HH, Pan WH, Yang CS, CJ CH, Yu MW, et al. Vegetable consumption, serum retinol level, and risk of hepatocellular carcinoma. Cancer Res. Mar 15. 1995;55(6):1301-5. Not eligible target population. [pmid: 7882326].
541 Yu MW, Lien JP, Chiu YH, Santella RM, Liaw YF, Chen CJ, et al. Effect of aflatoxin metabolism and DNA adduct formation on hepatocellular carcinoma among chronic hepatitis B carriers in Taiwan. Journal of Hepatology. Aug. 1997;27(2):320-30. Not relevant outcomes. [pmid: 9288607].
542 Yu MW, Lien JP, Liaw YF, Chen CJ, Yu MW, Lien JP, et al. Effects of multiple risk factors for hepatocellular carcinoma on formation of aflatoxin B1-DNA adducts. Cancer Epidemiol Biomarkers Prev. Aug. 1996;5(8):613-9. Not relevant outcomes. [pmid: 8824363].
543 Yuan Y, Iloeje U, Li H, Hay J, Yao GB. Economic implications of entecavir treatment in suppressing viral replication in chronic hepatitis B (CHB) patients in China from a perspective of the Chinese Social Security program. Value in Health. Mar. 2008;11(Suppl 1):S11-22. Not relevant outcomes. [pmid: 18387054].
544 Yuen MF, Fung SK, Tanaka Y, Kato T, Mizokami M, Yuen JC, et al. Longitudinal study of hepatitis activity and viral replication before and after HBeAg seroconversion in chronic hepatitis B patients infected with genotypes B and C. J Clin Microbiol. Nov. 2004;42(11):5036-40. Not relevant outcomes. [pmid: 15528692].
545 Yuen MF, Seto WK, Chow DH, Tsui K, Wong DK, Ngai VW, et al. Long-term lamivudine therapy reduces the risk of long-term complications of chronic hepatitis B infection even in patients without advanced disease. Antiviral Therapy. 2007;12(8):1295-303. Less than 1000 patients and not US study. [pmid: 18240869].
546 Yuen MF, Tam S, Fung J, Wong DK, Wong BC, Lai CL, et al. Traditional Chinese medicine causing hepatotoxicity in patients with chronic hepatitis B infection: a 1-year prospective study. Alimentary Pharmacology & Therapeutics. Oct 15. 2006;24(8):1179-86. Not relevant outcomes. [pmid: 17014576].
547 Zakaria S, Goldsmith RS, Kamel MA, el-Raziky EH, Zakaria S, Goldsmith RS, et al. The etiology of acute hepatitis in adults in Egypt. Trop Geogr Med. Oct. 1988;40(4):285-92. Not relevant outcomes. [pmid: 2852410].
548 Zaman A, Hapke R, Flora K, Rosen HR, Benner K, Zaman A, et al. Factors predicting the presence of esophageal or gastric varices in patients with advanced liver disease. American Journal of Gastroenterology. Nov. 1999;94(11):3292-6. Not eligible exposure. [pmid: 10566732].
549 Zaman SN, Melia WM, Johnson RD, Portmann BC, Johnson PJ, Williams R, et al. Risk factors in development of hepatocellular carcinoma in cirrhosis: prospective study of 613 patients. Lancet. Jun 15. 1985;1(8442):1357-60. Not relevant outcomes. [pmid: 2861313].
550 Zavaglia C, Airoldi A, Pinzello G, Zavaglia C, Airoldi A, Pinzello G. Antiviral therapy of HBV- and HCV-induced liver cirrhosis. J Clin Gastroenterol. Apr. 2000;30(3):234-41. Review. [pmid: 10777179].
551 Zhang JY, Chan EK, Peng XX, Tan EM, Zhang JY, Chan EK, et al. A novel cytoplasmic protein with RNA-binding motifs is an autoantigen in human hepatocellular carcinoma. J Exp Med. Apr 5. 1999;189(7):1101-10. Not eligible exposure. [pmid: 10190901].
552 Zheng S, Chen Y, Liang T, Lu A, Wang W, Shen Y, et al. Prevention of hepatitis B recurrence after liver transplantation using lamivudine or lamivudine combined with hepatitis B Immunoglobulin prophylaxis. Liver Transpl. Feb. 2006;12(2):253-8. Not eligible target population. [pmid: 16447195].
553 Zhong S, Tang MW, Yeo W, Liu C, Lo YM, Johnson PJ, et al. Silencing of GSTP1 gene by CpG island DNA hypermethylation in HBV-associated hepatocellular carcinomas. Clin Cancer Res. Apr. 2002;8(4):1087-92. Not relevant outcomes. [pmid: 11948118].
554 Zhong S, Yeo W, Tang MW, Wong N, Lai PB, Johnson PJ, et al. Intensive hypermethylation of the CpG island of Ras association domain family 1A in hepatitis B virus-associated hepatocellular carcinomas. Clin Cancer Res. Aug 15. 2003;9(9):3376-82. Not relevant outcomes. [pmid: 12960125].
555 Zhou J, Dore GJ, Zhang F, Lim PL, Chen YM, Database TAHO. Hepatitis B and C virus coinfection in The TREAT Asia HIV Observational Database. Journal of Gastroenterology & Hepatology. Sep. 2007;22(9):1510-8. Less than 1000 patients and not US study. [pmid: 17645479].
556 Zhu R, Huang H, Zhang H, Wang Z, Hu X, Zhai W, et al. Prognostic analysis in chronic hepatitis B patients: a retrospective study of 216 cases about Scheuer scores, in situ expression of viral antigens and tissue hepatitis B virus DNA levels. Liver International. Feb. 2006;26(1):82-9. Not relevant outcomes. [pmid: 16420513].
557 Zhu WF, Yin LM, Li P, Huang J, Zhuang H, Zhu WF, et al. Pathogenicity of GB virus C on virus hepatitis and hemodialysis patients. World J Gastroenterol. Aug. 2003;9(8):1739-42. Not relevant outcomes. [pmid: 12918111].
558 Zhu XD, Zhang WH, Li CL, Xu Y, Liang WJ, Tien P, et al. New serum biomarkers for detection of HBV-induced liver cirrhosis using SELDI protein chip technology. World J Gastroenterol. Aug 15. 2004;10(16):2327-9. Not relevant outcomes. [pmid: 15285013].
559 Zografos TA, Rigopoulou EI, Liaskos C, Togousidis E, Zachou K, Gatselis N, et al. Alterations of leptin during IFN-alpha therapy in patients with chronic viral hepatitis. Journal of Hepatology. May. 2006;44(5):848-55. Not relevant outcomes. [pmid: 16530290].
560 Zumbika E, Ruan B, Xu CH, Ni Q, Hou W, Chen Z, et al. HBV genotype characterization and distribution in patients with HBV-related liver diseases in Zhejiang Province, P.R. China: possible association of co-infection with disease prevalence and severity. Hepatobiliary Pancreat Dis Int. Nov. 2005;4(4):535-43. Not relevant outcomes. [pmid: 16286258].

## Key Questions 2–4

1 Ahman L, Back E, Bensch K, et al. Non-efficacy of low-dose intradermal vaccination against hepatitis B in Down's syndrome. Scand J Infect Dis. 1993;25(1):16-23. Not eligible target population. [pmid: 8460344].
2 Ajgaonkar VS, Mogre VM. Ribavirin in acute viral hepatitis. Indian J Gastroenterol. Jul. 1991;10(3):90-1. Not eligible target population. [pmid: 1916970].
3 Akuta N, Suzuki F, Kobayashi M, et al. Virological and biochemical relapse after discontinuation of lamivudine monotherapy for chronic hepatitis B in Japan: comparison with breakthrough hepatitis during long-term treatment. Intervirology. Mar–Jun. 2005;48(23):174-82. Not eligible outcomes. [pmid: 15812192].
4 Akuta N, Suzuki F, Suzuki Y, et al. Favorable efficacy of long-term lamivudine therapy in patients with chronic hepatitis B: an 8-year follow-up study. J Med Virol. Apr. 2005;75(4):491-8. Case-series. [pmid: 15714490].
5 Akuta N, Suzuki F, Tsubota A, et al. Long-term clinical remission induced by corticosteroid withdrawal therapy (CSWT) in patients with chronic hepatitis B infection: a prospective randomized controlled trial—CSWT with and without follow-up interferon-alpha therapy. Dig Dis Sci. Feb. 2002;47(2):405-14. Unapproved itnervention. [pmid: 11855559].
6 Albers R, van der Wielen RP, Brink EJ, et al. Effects of cis-9, trans-11 and trans-10, cis-12 conjugated linoleic acid (CLA) isomers on immune function in healthy men. Eur J Clin Nutr. Apr. 2003;57(4):595-603. Not eligible target population. [pmid: 12700622].
7 Ali HY. Trial of lamivudine in hepatitis B surface antigen carriers with persistent hepatitis B core IgM antibody. Saudi Med J. Sep. 2003;24(9):996-9. Not eligible target population. [pmid: 12973486].
8 Amarapurkar DN, Patel ND. Combination of Peginterferon alpha-2b (12 kDa) and Lamivudine in difficult-to-treat chronic hepatitis B- an Indian experience. Ann Hepatol. Jan–Mar. 2005;4(1):56-9. Case-series. [pmid: 15798663].
9 Ambrosch F, Andre FE, Delem A, et al. Simultaneous vaccination against hepatitis A and B: results of a controlled study. Vaccine. 1992;10(Suppl 1):S142-5. Not eligible target population. [pmid: 1335647].
10 Ambrosch F, Wiedermann G, Kundi M, et al. A hepatitis B vaccine formulated with a novel adjuvant system. Vaccine. Apr 14. 2000;18(20):2095-101. Not eligible target population. [pmid: 10715523].
11 Anandh U, Bastani B, Ballal S. Granulocyte-macrophage colony-stimulating factor as an adjuvant to hepatitis B vaccination in maintenance hemodialysis patients. Am J Nephrol. Jan–Feb. 2000;20(1):53-6. Not eligible target population. [pmid: 10644869].
12 Anandh U, Thomas PP, Shastry JC, et al. A randomised controlled trial of intradermal hepatitis B vaccination and augmentation of response with erythropoietin. J Assoc Physicians India. Nov. 2000;48(11):1061-3. Not eligible target population. [pmid: 11310381].
13 Ando E, Kuromatsu R, Tanaka M, et al. Surveillance program for early detection of hepatocellular carcinoma in Japan: results of specialized department of liver disease. J Clin Gastroenterol. Nov–Dec. 2006;40(10):942-8. Not eligible exposure. [pmid: 17063116].
14 Andreone P, Cursaro C, Gramenzi A, et al. A randomized controlled trial of thymosin-alpha1 versus interferon alfa treatment in patients with hepatitis B e antigen antibody—and hepatitis B virus DNA—positive chronic hepatitis B. Hepatology. Oct. 1996;24(4):774-7. Unapproved itnervention. [pmid: 8855175].
15 Andreone P, Fiorino S, Cursaro C, et al. Vitamin E as treatment for chronic hepatitis B: results of a randomized controlled pilot trial. Antiviral Res. Feb. 2001;49(2):75-81. Not eligible exposure. [pmid: 11248360].
16 Andresen I, Kovarik JM, Spycher M, et al. Product equivalence study comparing the tolerability, pharmacokinetics, and pharmacodynamics of various human immunoglobulin-G formulations. J Clin Pharmacol. Jul. 2000;40(7):722-30. Not eligible target population. [pmid: 10883413].
17 Angel JB, Jacobson MA, Skolnik PR, et al. A multicenter, randomized, double-blind, placebo-controlled trial of recombinant human interleukin-10 in HIV-infected subjects. AIDS. Nov 10. 2000;14(16):2503-8. Not eligible target population. [pmid: 11101061].
18 Arase Y, Chayama K, Tsubota A, et al. A randomized, double-blind, controlled trial of natural interferon-beta therapy for e-antigen-negative chronic hepatitis B patients with abnormal transaminase levels. J Gastroenterol. Aug. 1996;31(4):559-64. Unapproved itnervention. [pmid: 8844478].
19 Arase Y, Tsubota A, Suzuki Y, et al. A pilot study of thymosin alpha1 therapy for chronic hepatitis B patients. Intern Med. Oct. 2003;42(10):941-6. Unapproved itnervention. [pmid: 14606705].
20 Arbizu EA, Marugan RB, Grijalba JY, et al. Intramuscular versus intradermal administration of anti-hepatitis B vaccine in non-cirrhotic hepatitis C patients. Vaccine. Jun 20. 2003;21(2122):2747-50. Not eligible target population. [pmid: 12798613].
21 Artillo S, Pastore G, Alberti A, et al. Double-blind, randomized controlled trial of interleukin-2 treatment of chronic hepatitis B. J Med Virol. Mar. 1998;54(3):167-72. Not eligible exposure. [pmid: 9580313].
22 Averhoff F, Mahoney F, Coleman P, et al. Immunogenicity of hepatitis B Vaccines. Implications for persons at occupational risk of hepatitis B virus infection. Am J Prev Med. Jul. 1998;15(1):1-8. Not eligible target population.
23 Ayaz C, Celen MK, Colak H, et al. Comparison of lamivudine and alpha-interferon combination with alpha-interferon alone in the treatment of HBeAg-positive chronic hepatitis B. Indian J Gastroenterol. Mar–Apr. 2006;25(2):71-3. Unapproved itnervention. [pmid: 16763334].
24 Bahrami H, Daryani NE, Haghpanah B, et al. Effects of indomethacin on viral replication markers in asymptomatic carriers of hepatitis B: a randomized, placebo-controlled trial. Am J Gastroenterol. Apr. 2005;100(4):856-61. Not eligible exposure. [pmid: 15784032].
25 Baicus C, Tanasescu C. Chronic viral hepatitis, the treatment with spiruline for one month has no effect on the aminotransferases. Rom J Intern Med. 2002;40(14):89-94. Not eligible exposure. [pmid: 15526544].
26 Baltayiannis G, Katsanos K, Karayiannis P, et al. Interferon-alpha therapy in HBeAg-negative chronic hepatitis B: a long-term prospective study from north-western Greece. Aliment Pharmacol Ther. Aug 1. 2006;24(3):525-33. Not eligible outcomes. [pmid: 16886919].
27 Bayraktar Y, Koseoglu T, Somner C, et al. The use of deferoxamine infusions to enhance the response rate to interferon-alpha treatment of chronic viral hepatitis B. J Viral Hepat. May. 1996;3(3):129-35. Not eligible exposure. [pmid: 8871871].
28 Bayraktar Y, Saglam F, Temizer A, et al. The effect of interferon and desferrioxamine on serum ferritin and hepatic iron concentrations in chronic hepatitis B. Hepatogastroenterology. Nov–Dec. 1998;45(24):2322-7. Not eligible exposure. [pmid: 9951916].
29 Bayraktar Y, Uzunalimoglu B, Arslan S, et al. Effects of recombinant alpha interferon on chronic active hepatitis B: preliminary results. Gut. 1993;34(2 Suppl):S101. Small sample size. [pmid: 8314468].
30 Beinker NK, Voigt MD, Arendse M, et al. Threshold effect of liver iron content on hepatic inflammation and fibrosis in hepatitis B and C. J Hepatol. Nov. 1996;25(5):633-8. Case-series. [pmid: 8938538].
31 Bennett RG, Powers DC, Remsburg RE, et al. Hepatitis B virus vaccination for older adults. J Am Geriatr Soc. Jun. 1996;44(6):699-703. Not eligible target population. [pmid: 8642163].
32 Berk L, de Man RA, Schalm SW, et al. Beneficial effects of Phyllanthus amarus for chronic hepatitis B, not confirmed. J Hepatol. May. 1991;12(3):405-6. Not eligible exposure. [pmid: 1940272].
33 Berk L, Schalm SW, de Man RA, et al. Failure of acyclovir to enhance the antiviral effect of alpha lymphoblastoid interferon on HBe-seroconversion in chronic hepatitis B. A multi-centre randomized controlled trial. J Hepatol. Mar. 1992;14(23):305-9. Unapproved itnervention. [pmid: 1500694].
34 Bertino JS Jr, Tirrell P, Greenberg RN, et al. A comparative trial of standard or high-dose S subunit recombinant hepatitis B vaccine versus a vaccine containing S subunit, pre-S1, and pre-S2 particles for revaccination of healthy adult nonresponders. J Infect Dis. Mar. 1997;175(3):678-81. Not eligible target population. [pmid: 9041342].
35 Bessesen M, Ives D, Condreay L, et al. Chronic active hepatitis B exacerbations in human immunodeficiency virus-infected patients following development of resistance to or withdrawal of lamivudine. Clin Infect Dis. May. 1999;28(5):1032-5. Case Reports. [pmid: 10452630].
36 Bhimma R, Coovadia HM, Ramjee G, et al. Characterization of proteinuria in asymptomatic family members and household contacts of children with hepatitis B virus-associated membranous nephropathy. Am J Kidney Dis. Jan. 2001;37(1):125-33. Not eligible target population. [pmid: 11136177].
37 Blajchman MA, Bull SB, Feinman SV. Post-transfusion hepatitis: impact of non-A, non-B hepatitis surrogate tests. Canadian Post-Transfusion Hepatitis Prevention Study Group. Lancet. Jan 7. 1995;345(8941):21-5. Not eligible target population. [pmid: 7528310].
38 Bock HL. Rapid hepatitis B immunisation for the traveller: comparison of two accelerated schedules with a 2-month schedule. BioDrugs. 2003;17(Suppl 1):11-3. Not eligible target population. [pmid: 12785872].
39 Boland G, Beran J, Lievens M, et al. Safety and immunogenicity profile of an experimental hepatitis B vaccine adjuvanted with AS04. Vaccine. Dec 2. 2004;23(3):316-20. Not eligible target population. [pmid: 15530674].
40 Boland GJ, van Bommel T, Rulos-van den Berg A, et al. The efficacy of a two-dose hepatitis B vaccination scheme. Adv Exp Med Biol. 2003;531:185-90. Not eligible target population. [pmid: 12916790].
41 Bortolotti F, Jara P, Crivellaro C, et al. Outcome of chronic hepatitis B in Caucasian children during a 20-year observation period. J Hepatol. Aug. 1998;29(2):184-90. Not eligible target population. [pmid: 9722198].
42 Bosch O, Moraleda G, Castillo I, et al. Treatment of chronic hepatitis B with recombinant interferon alpha versus recombinant interferon alpha plus levamisole. J Hepatol. Nov. 1993;19(3):437-41. Unapproved itnervention. [pmid: 8151105].
43 Bozkaya H, Yurdaydin C, Idilman R, et al. Lamivudine treatment in HBeAg-negative chronic hepatitis B patients with low level viraemia. Antivir Ther. 2005;10(2):319-25. Not eligible outcomes. [pmid: 15865226].
44 Brissot P, Jacquelinet C, Jouanolle H, et al. Short-term prednisolone followed by recombinant human alpha-interferon alone or combined with adenine-arabinoside in chronic hepatitis B. A prospective and randomized trial. J Hepatol. Mar. 1991;12(2):181-9. Not eligible exposure. [pmid: 2050997].
45 Brodersen HP, Holtkamp W, Larbig D, et al. Zinc supplementation and hepatitis B vaccination in chronic haemodialysis patients: a multicentre study. Nephrol Dial Transplant. 1995;10(9):1780. Not eligible target population. [pmid: 8559509].
46 Brook MG, Main J, Yap I, et al. Short report: prednisolone withdrawal followed by lymphoblastoid interferon in the therapy of adult patients with presumed childhood-acquired chronic hepatitis B virus infection. Aliment Pharmacol Ther. Jun. 1993;7(3):331-6. Unapproved itnervention. [pmid: 8364139].
47 Bruch HR, Korn A, Klein H, et al. Treatment of chronic hepatitis B with interferon alpha-2b and interleukin-2. J Hepatol. 1993;17(Suppl 3):S52-5. Unapproved itnervention. [pmid: 8509640].
48 Bruguera M, Bayas JM, Vilella A, et al. Immunogenicity and reactogenicity of a combined hepatitis A and B vaccine in young adults. Vaccine. Oct. 1996;14(15):1407-11. Not eligible target population. [pmid: 8994314].
49 Bruguera M, Rodicio JL, Alcazar JM, et al. Effects of different dose levels and vaccination schedules on immune response to a recombinant DNA hepatitis B vaccine in haemodialysis patients. Vaccine. Mar. 1990;8(Suppl):S47-9. discussion S60–2. Not eligible target population. [pmid: 2139283].
50 Brunetto MR, Giarin M, Saracco G, et al. Hepatitis B virus unable to secrete e antigen and response to interferon in chronic hepatitis B. Gastroenterology. Sep. 1993;105(3):845-50. Unapproved itnervention. [pmid: 7689519].
51 Bryan JP, Craig PG, Reyes L, et al. Randomized comparison of 5 and 10 microgram doses of two recombinant hepatitis B vaccines. Vaccine. Aug. 1995;13(11):978-82. Not eligible target population. [pmid: 8525691].
52 Bryan JP, McCardle P, South-Paul JE, et al. Randomized controlled trial of concurrent hepatitis A and B vaccination. Mil Med. Feb. 2001;166(2):95-101. Not eligible target population. [pmid: 11272721].
53 Bryan JP, Sjogren M, Iqbal M, et al. Comparative trial of low-dose, intradermal, recombinant- and plasma-derived hepatitis B vaccines. J Infect Dis. Oct. 1990;162(4):789-93. Not eligible target population. [pmid: 2144866].
54 Bukhari NI, Aziz MT, Jamshaid M. Comparative immunogenicity of a genetically derived and a plasma pooled hepatitis B vaccine in normal adult volunteers. Therapie. May–Jun. 2005;60(3):311-6. Not eligible target population. [pmid: 16128276].
55 Bush LM, Moonsammy GI, Boscia JA. Evaluation of initiating a hepatitis B vaccination schedule with one vaccine and completing it with another. Vaccine. Nov. 1991;9(11):807-9. Not eligible target population. [pmid: 1836921].
56 Buti M, Jardi R, Rodriguez-Frias F, et al. Interferon vs. adenine arabinoside 5′-monophosphate in patients with anti-HBe-positive chronic hepatitis. J Med Virol. Aug. 1996;49(4):325-8. Unapproved itnervention. [pmid: 8877766].
57 Buti M, Mas A, Prieto M, et al. A randomized study comparing lamivudine monotherapy after a short course of hepatitis B immune globulin (HBIg) and lamivudine with long-term lamivudine plus HBIg in the prevention of hepatitis B virus recurrence after liver transplantation. J Hepatol. Jun. 2003;38(6):811-7. Not eligible target population. [pmid: 12763375].
58 Cadranel JF, Di Martino V, Dorent R, et al. Effects of ursodeoxycholic acid (ursodiol) treatment on chronic viral hepatitis in heart transplant patients: results of a prospective, double-blind, placebo-randomized study. Transplantation. Apr 15. 2003;75(7):977-82. Not eligible target population. [pmid: 12698083].
59 Cameron DW, Japour AJ, Xu Y, et al. Ritonavir and saquinavir combination therapy for the treatment of HIV infection. AIDS. Feb 4. 1999;13(2):213-24. Not eligible exposure. [pmid: 10202827].
60 Capalbo M, Palmisano L, Bonino F, et al. Intramuscular natural beta interferon in the treatment of chronic hepatitis B: a multicentre trial. Italian Hepatitis B Study Group. Ital J Gastroenterol. Jun. 1994;26(5):238-41. Unapproved itnervention. [pmid: 7919465].
61 Carreno V, Marcellin P, Hadziyannis S, et al. Retreatment of chronic hepatitis B e antigen-positive patients with recombinant interferon alfa-2a. The European Concerted Action on Viral Hepatitis (EUROHEP). Hepatology. Jul. 1999;30(1):277-82. Unapproved itnervention. [pmid: 10385667].
62 Carreno V, Moreno A, Galiana F, et al. Alpha- and gamma-interferon versus alpha-interferon alone in chronic hepatitis B. A randomized controlled study. J Hepatol. Mar. 1993;17(3):321-5. Not eligible exposure. [pmid: 8315260].
63 Carreno V, Zeuzem S, Hopf U, et al. A phase I/II study of recombinant human interleukin-12 in patients with chronic hepatitis B. J Hepatol. Feb. 2000;32(2):317-24. Not eligible exposure. [pmid: 10707873].
64 Cassidy WM, Watson B, Ioli VA, et al. A randomized trial of alternative two- and three-dose hepatitis B vaccination regimens in adolescents: antibody responses, safety, and immunologic memory. Pediatrics. Apr. 2001;107(4):626-31. Not eligible target population. [pmid: 11335734].
65 Catterall AP, King R, Lau JY, et al. Interferon-alpha therapy with and without interferon-alpha priming in patients with chronic hepatitis B infection. J Antimicrob Chemother. May. 1993;31(5):777-82. Unapproved itnervention. [pmid: 8335505].
66 Chalasani N, Gitlin N. Why do we need a newer generation of recombinant vaccines against hepatitis B?. Am J Gastroenterol. Dec. 1997;92(12):2314-5. Not eligible target population. [pmid: 9399785].
67 Chan C, Abu-Raddad E, Golor G, et al. Clinical pharmacokinetics of alamifovir and its metabolites. Antimicrob Agents Chemother. May. 2005;49(5):1813-22. Not eligible target population. [pmid: 15855501].
68 Chan HL, Sung JJ, Fong WF, et al. Double-blinded placebo-controlled study of Phyllanthus urinaris for the treatment of chronic hepatitis B. Aliment Pharmacol Ther. Aug 1. 2003;18(3):339-45. Not eligible exposure. [pmid: 12895219].
69 Chang PC, Schrander-van der Meer AM, van Dorp WT, et al. Intracutaneous versus intramuscular hepatitis B vaccination in primary non-responding haemodialysis patients. Nephrol Dial Transplant. Jan. 1996;11(1):191-3. Not eligible target population. [pmid: 8649634].
70 Chang TT, Lai CL, Chien RN, et al. Four years of lamivudine treatment in Chinese patients with chronic hepatitis B. J Gastroenterol Hepatol. Nov. 2004;19(11):1276-82. RCT reported as case-series. [pmid: 15482535].
71 Charest AF, McDougall J, Goldstein MB. A randomized comparison of intradermal and intramuscular vaccination against hepatitis B virus in incident chronic hemodialysis patients. Am J Kidney Dis. Nov. 2000;36(5):976-82. Not eligible target population. [pmid: 11054354].
72 Chau KF, Cheng YL, Tsang DN, et al. Efficacy and side effects of intradermal hepatitis B vaccination in CAPD patients: a comparison with the intramuscular vaccination. Am J Kidney Dis. May. 2004;43(5):910-7. Not eligible target population. [pmid: 15112182].
73 Chen C, Guo SM, Liu B. A randomized controlled trial of kurorinone versus interferon-alpha2a treatment in patients with chronic hepatitis B. J Viral Hepat. May. 2000;7(3):225-9. Not eligible exposure. [pmid: 10849265].
74 Chen DK, Yim C, O'Rourke K, et al. Long-term follow-up of a randomized trial of interferon therapy for chronic hepatitis B in a predominantly homosexual male population. J Hepatol. Apr. 1999;30(4):557-63. Unapproved itnervention. [pmid: 10207795].
75 Chen JG, Parkin DM, Chen QG, et al. Screening for liver cancer: results of a randomised controlled trial in Qidong, China. J Med Screen. 2003;10(4):204-9. Not eligible target population. [pmid: 14738659].
76 Chen M, Li YG, Zhang DZ, et al. Therapeutic effect of autologous dendritic cell vaccine on patients with chronic hepatitis B: a clinical study. World J Gastroenterol. Mar 28. 2005;11(12):1806-8. Not eligible exposure. [pmid: 15793869].
77 Chen RY, Bowden S, Desmond PV, et al. Effects of interferon alpha therapy on the catalytic domains of the polymerase gene and basal core promoter, precore and core regions of hepatitis B virus. J Gastroenterol Hepatol. Jun. 2003;18(6):630-7. Case-series. [pmid: 12753143].
78 Chen ZX, Zhang SJ, Lao SX, et al. He Jie Tang in the treatment of chronic hepatitis B patients. World J Gastroenterol. Nov 14. 2005;11(42):6638-43. Not eligible exposure. [pmid: 16425357].
79 Cheng AL, Hsiung CA, Su IJ, et al. Steroid-free chemotherapy decreases risk of hepatitis B virus (HBV) reactivation in HBV-carriers with lymphoma. Hepatology. Jun. 2003;37(6):1320-8. Not eligible exposure. [pmid: 12774010].
80 Chien RN, Liaw YF. Short-term lamivudine therapy in HBeAg-negative chronic active hepatitis B in Taiwan. Antivir Ther. 2006;11(7):947-52. Case-series. [pmid: 17302259].
81 Chien RN, Liaw YF, Chen TC, et al. Efficacy of thymosin alpha1 in patients with chronic hepatitis B: a randomized, controlled trial. Hepatology. May. 1998;27(5):1383-7. Unapproved itnervention. [pmid: 9581695].
82 Chien RN, Lin CY, Yeh CT, et al. Hepatitis B virus genotype B is associated with better response to thymosin alpha1 therapy than genotype C. J Viral Hepat. Dec. 2006;13(12):845-50. Unapproved itnervention. [pmid: 17109685].
83 Chien RN, Yang LJ, Lin PY, et al. Hepatic injury during ketoconazole therapy in patients with onychomycosis: a controlled cohort study. Hepatology. Jan. 1997;25(1):103-7. Not eligible target population. [pmid: 8985273].
84 Chowdhury A, Santra A, Habibullah CM, et al. Immune response to an indigenously developed r-hepatitis B vaccine in mixed population: study of an accelerated vaccination schedule. World J Gastroenterol. Feb 21. 2005;11(7):1037-9. Not eligible target population. [pmid: 15742410].
85 Chowdhury A, Shah S, Babu S, et al. Safety and efficacy of an indigenous human recombinant interferon alpha 2b (Shanferon) in patients with chronic hepatitis B. Trop Gastroenterol. Apr–Jun. 2005;26(2):70-2. Case-series. [pmid: 16225048].
86 Christensen PB, Fisker N, Krarup HB, et al. Hepatitis B vaccination in prison with a 3-week schedule is more efficient than the standard 6-month schedule. Vaccine. Sep 28. 2004;22(2930):3897-901. Not eligible target population. [pmid: 15364437].
87 Cividini A, Pistorio A, Regazzetti A, et al. Hepatitis C virus infection among institutionalised psychiatric patients: a regression analysis of indicators of risk. J Hepatol. Sep. 1997;27(3):455-63. Not eligible target population. [pmid: 9314121].
88 Clements ML, Miskovsky E, Davidson M, et al. Effect of age on the immunogenicity of yeast recombinant hepatitis B vaccines containing surface antigen (S) or PreS2 + S antigens. J Infect Dis. Sep. 1994;170(3):510-6. Not eligible target population. [pmid: 8077707].
89 Clements-Mann ML, Dudas R, Hoshino Y, et al. Safety and immunogenicity of live attenuated quadrivalent human-bovine (UK) reassortant rotavirus vaccine administered with childhood vaccines to infants. Vaccine. Sep 14. 2001;19(32):4676-84. Not eligible target population. [pmid: 11535316].
90 Coleman PJ, Shaw FE Jr, Serovich J, et al. Intradermal hepatitis B vaccination in a large hospital employee population. Vaccine. Oct. 1991;9(10):723-7. Not eligible target population. [pmid: 1836918].
91 Connor BA, Blatter MM, Beran J, et al. Rapid and sustained immune response against hepatitis A and B achieved with combined vaccine using an accelerated administration schedule. J Travel Med. Jan–Feb. 2007;14(1):9-15. Not eligible target population. [pmid: 17241248].
92 Cooksley G. Does the addition of lamivudine to peginterferon alpha-2a sustain response rates in HBeAg-negative hepatitis B?. Nat Clin Pract Gastroenterol Hepatol. Jan. 2005;2(1):12-3. Comment. [pmid: 16265091].
93 Cooper CL, Davis HL, Angel JB, et al. CPG 7909 adjuvant improves hepatitis B virus vaccine seroprotection in antiretroviral-treated HIV-infected adults. AIDS. Sep 23. 2005;19(14):1473-9. Not eligible target population. [pmid: 16135900].
94 Cooper CL, Davis HL, Morris ML, et al. CPG 7909, an immunostimulatory TLR9 agonist oligodeoxynucleotide, as adjuvant to Engerix-B HBV vaccine in healthy adults: a double-blind phase I/II study. J Clin Immunol. Nov. 2004;24(6):693-701. Not eligible target population. [pmid: 15622454].
95 Czeschinski PA, Binding N, Witting U. Hepatitis A and hepatitis B vaccinations: immunogenicity of combined vaccine and of simultaneously or separately applied single vaccines. Vaccine. Jan 6. 2000;18(1112):1074-80. Not eligible target population. [pmid: 10590328].
96 Da Silva LC, da Fonseca LE, Carrilho FJ, et al. Predictive factors for response to lamivudine in chronic hepatitis B. Rev Inst Med Trop Sao Paulo. Jul–Aug. 2000;42(4):189-96. Case-series. [pmid: 10968881].
97 Da Villa G, Picciotto L, Ribera G, et al. Effective antibody response in newborn babies living in Maldives to simultaneous vaccination against hepatitis B, poliomyelitis, diphtheria and tetanus. Vaccine. Jun. 1995;13(9):795-8. Not eligible target population. [pmid: 7483799].
98 Dal-Re R, Gonzalez A, Ramirez V, et al. Compliance with immunization against hepatitis B. A pragmatic study in sexually transmitted disease clinics. Vaccine. Feb. 1995;13(2):163-7. Not eligible target population. [pmid: 7625110].
99 d'Alteroche L, Majzoub S, Lecuyer AI, et al. Ophthalmologic side effects during alpha-interferon therapy for viral hepatitis. J Hepatol. Jan. 2006;44(1):56-61. Not eligible target population. [pmid: 16223542].
100 Danel C, Moh R, Anzian A, et al. Tolerance and acceptability of an efavirenz-based regimen in 740 adults (predominantly women) in West Africa. J Acquir Immune Defic Syndr. May. 2006;42(1):29-35. Not eligible target population. [pmid: 16763490].
101 Das HS, Sawant P, Shirhatti RG, et al. Efficacy of low dose intradermal hepatitis B vaccine: results of a randomized trial among health care workers. Trop Gastroenterol. Jul–Sep. 2002;23(3):120-1. Not eligible target population. [pmid: 12693152].
102 Dawson S 3rd, Imagawa DK, Johnson C, et al. UCLA liver transplantation: analysis of immunological factors affecting outcome. Artif Organs. Oct. 1996;20(10):1063-72. Not eligible target population. [pmid: 8896726].
103 de Maat MM, Huitema AD, Mulder JW, et al. Population pharmacokinetics of nevirapine in an unselected cohort of HIV-1-infected individuals. Br J Clin Pharmacol. Oct. 2002;54(4):378-85. Not eligible target population. [pmid: 12392585].
104 de Man RA, Marcellin P, Habal F, et al. A randomized, placebo-controlled study to evaluate the efficacy of 12-month famciclovir treatment in patients with chronic hepatitis B e antigen-positive hepatitis B. Hepatology. Aug. 2000;32(2):413-7. Unapproved itnervention. [pmid: 10915751].
105 Demirci M, Isler M, Cicioglu Aridogan B, et al. Coinfection of chronic hepatitis B and fasciolosis. Infection. Feb. 2004;32(1):54-6. Case Reports. [pmid: 15007744].
106 Deng YQ, Fan XF, Li YD. Clinical observation of the effect of Xuesaitong soft capsule on post-hepatitis fibrosis. Chin J Integr Med. Mar. 2005;11(1):11-4. Not eligible exposure. [pmid: 15975300].
107 Deniz Ayli M, Ensari C, Ayli M, et al. Effect of oral levamisole supplementation to hepatitis B vaccination on the rate of immune response in chronic hemodialysis patients. Nephron. Mar. 2000;84(3):291-2. Not eligible target population. [pmid: 10720909].
108 Desombere I, Van der Wielen M, Van Damme P, et al. Immune response of HLA DQ2 positive subjects, vaccinated with HBsAg/AS04, a hepatitis B vaccine with a novel adjuvant. Vaccine. Jun 7. 2002;20(1920):2597-602. Not eligible target population. [pmid: 12057618].
109 Di Marco V, Marzano A, Lampertico P, et al. Clinical outcome of HBeAg-negative chronic hepatitis B in relation to virological response to lamivudine. Hepatology. Oct. 2004;40(4):883-91. No associative hypothesis tested. [pmid: 15382125].
110 Dienstag JL, Perrillo RP, Schiff ER, et al. A preliminary trial of lamivudine for chronic hepatitis B infection. N Engl J Med. Dec 21. 1995;333(25):1657-61. Small sample size. [pmid: 7477217].
111 Ding HG, Shan J, Zhang B, et al. Combined human growth hormone and lactulose for prevention and treatment of multiple organ dysfunction in patients with severe chronic hepatitis B. World J Gastroenterol. May 21. 2005;11(19):2981-3. Not eligible exposure. [pmid: 15902741].
112 Dolin R, Graham BS, Greenberg SB, et al. The safety and immunogenicity of a human immunodeficiency virus type 1 (HIV-1) recombinant gp160 candidate vaccine in humans. NIAID AIDS Vaccine Clinical Trials Network. Ann Intern Med. Jan 15. 1991;114(2):119-27. Not eligible target population. [pmid: 1984386].
113 Dore GJ, Cooper DA, Barrett C, et al. Dual efficacy of lamivudine treatment in human immunodeficiency virus/hepatitis B virus-coinfected persons in a randomized, controlled study (CAESAR). The CAESAR Coordinating Committee. J Infect Dis. Sep. 1999;180(3):607-13. Unapproved itnervention. [pmid: 10438346].
114 Dore GJ, Cooper DA, Pozniak AL, et al. Efficacy of tenofovir disoproxil fumarate in antiretroviral therapy-naive and -experienced patients coinfected with HIV-1 and hepatitis B virus. J Infect Dis. Apr 1. 2004;189(7):1185-92. Not eligible exposure, pending FDA approval, spring 2008. [pmid: 15031786].
115 Douvin C, Simon D, Charles MA, et al. Hepatitis B vaccination in diabetic patients. Randomized trial comparing recombinant vaccines containing and not containing pre-S2 antigen. Diabetes Care. Feb. 1997;20(2):148-51. Not eligible target population. [pmid: 9118762].
116 Dukes CS, Street AC, Starling JF, et al. Hepatitis B vaccination and booster in predialysis patients: a 4-year analysis. Vaccine. Sep. 1993;11(12):1229-32. Not eligible target population. [pmid: 8256504].
117 Dumann H, Meuer SC, Renschin G, et al. Influence of thymopentin on antibody response, and monocyte and T cell function in hemodialysis patients who fail to respond to hepatitis B vaccination. Nephron. 1990;55(2):136-40. Not eligible target population. [pmid: 2194133].
118 Dupont J, Altclas J, Lepetic A, et al. A controlled clinical trial comparing the safety and immunogenicity of a new adjuvanted hepatitis B vaccine with a standard hepatitis B vaccine. Vaccine. Nov 30. 2006;24(4950):7167-74. Not eligible target population. [pmid: 16884836].
119 Edelman R, Wasserman SS, Bodison SA, et al. Phase II safety and immunogenicity study of type F botulinum toxoid in adult volunteers. Vaccine. Oct 1. 2003;21(2730):4335-47. Not eligible target population. [pmid: 14505916].
120 Elefsiniotis IS, Moulakakis A, Pantazis KD, et al. Relationship between serum b2-microglobulin levels and virological breakthrough in HBeAg-negative chronic hepatitis B patients, under long-term treatment schedules including lamivudine. World J Gastroenterol. Apr 7. 2005;11(13):1922-8. Unapproved itnervention. [pmid: 15800981].
121 el-Reshaid K, al-Mufti S, Johny KV, et al. Comparison of two immunization schedules with recombinant hepatitis B vaccine and natural immunity acquired by hepatitis B infection in dialysis patients. Vaccine. 1994;12(3):223-34. Not eligible target population. [pmid: 8165854].
122 El-Zayadi A, Osaima S, Haseeb N, et al. Controlled trial with human lymphoblastoid interferon among HBeAg and anti-HBe-positive chronic hepatitis B patients in Egypt. J Egypt Public Health Assoc. 1995;70(56):579-94. Unapproved itnervention. [pmid: 17214176].
123 Estevez ZC, Betancourt AA, Muzio Gonzalez V, et al. Immunogenicity and safety assessment of the Cuban recombinant hepatitis B vaccine in healthy adults. Biologicals. Apr. 2007;35(2):115-22. Not eligible target population. [pmid: 17056272].
124 Evans TG, Hasan M, Galibert L, et al. The use of Flt3 ligand as an adjuvant for hepatitis B vaccination of healthy adults. Vaccine. Dec 13. 2002;21(34):322-9. Not eligible target population. [pmid: 12450708].
125 Evans TG, Schiff M, Graves B, et al. The safety and efficacy of GM-CSF as an adjuvant in hepatitis B vaccination of chronic hemodialysis patients who have failed primary vaccination. Clin Nephrol. Aug. 2000;54(2):138-42. Not eligible target population. [pmid: 10968690].
126 Eyigun CP, Yilmaz S, Gul C, et al. A comparative trial of two surface subunit recombinant hepatitis B vaccines vs a surface and PreS subunit vaccine for immunization of healthy adults. J Viral Hepat. Jul. 1998;5(4):265-9. Not eligible target population. [pmid: 9751013].
127 Fabrizi F, Andrulli S, Bacchini G, et al. Intradermal versus intramuscular hepatitis b re-vaccination in non-responsive chronic dialysis patients: a prospective randomized study with cost-effectiveness evaluation. Nephrol Dial Transplant. Jun. 1997;12(6):1204-11. Not eligible target population. [pmid: 9198052].
128 Farci P, Roskams T, Chessa L, et al. Long-term benefit of interferon alpha therapy of chronic hepatitis D: regression of advanced hepatic fibrosis. Gastroenterology. Jun. 2004;126(7):1740-9. Not eligible target population. [pmid: 15188169].
129 Fattovich G, Farci P, Rugge M, et al. A randomized controlled trial of lymphoblastoid interferon-alpha in patients with chronic hepatitis B lacking HBeAg. Hepatology. Apr. 1992;15(4):584-9. Unapproved itnervention. [pmid: 1551634].
130 Fattovich G, Giustina G, Alberti A, et al. A randomized controlled trial of thymopentin therapy in patients with chronic hepatitis B. J Hepatol. Sep. 1994;21(3):361-6. Unapproved itnervention. [pmid: 7836705].
131 Fattovich G, Giustina G, Brollo L, et al. Therapy for chronic hepatitis B with lymphoblastoid interferon-alpha and levamisole. Hepatology. Nov. 1992;16(5):1115-9. Unapproved itnervention. [pmid: 1427652].
132 Fei GZ, Sylvan SP, Yao GB, et al. Quantitative monitoring of serum hepatitis B virus DNA and blood lymphocyte subsets during combined prednisolone and interferon-alpha therapy in patients with chronic hepatitis B. J Viral Hepat. May. 1999;6(3):219-27. Case-series. [pmid: 10607234].
133 Flanagan JR, Doebbeling BN, Dawson J, et al. Randomized study of online vaccine reminders in adult primary care. Proc AMIA Symp 1999:755–9. Not eligible target population
134 Flisiak R, Prokopowicz D. Effect of misoprostol on the course of viral hepatitis B. Hepatogastroenterology. Sep–Oct. 1997;44(17):1419-25. Not eligible exposure. [pmid: 9356866].
135 Flisiak R, Prokopowicz D. Effect of misoprostol on serum beta2-microglobulin in the course of viral hepatitis B. Eur J Gastroenterol Hepatol. Nov. 1999;11(11):1227-30. Not eligible exposure. [pmid: 10563531].
136 Floreani A, Colloredo G, Lobello S, et al. Preliminary results of a two-center trial with colchicine for the treatment of chronic hepatitis B. Am J Gastroenterol. Dec. 2001;96(12):3451-2. Letter. [pmid: 11774977].
137 Fonseca MO, Pang LW, de Paula Cavalheiro N, et al. Randomized trial of recombinant hepatitis B vaccine in HIV-infected adult patients comparing a standard dose to a double dose. Vaccine. Apr 22. 2005;23(22):2902-8. Not eligible target population. [pmid: 15780739].
138 Fonseca V, Thomas M, Dusheiko G. Thyrotropin receptor antibodies following treatment with recombinant alpha-interferon in patients with hepatitis. Acta Endocrinol (Copenh). Nov. 1991;125(5):491-3. Not eligible outcomes. [pmid: 1759538].
139 Frey S, Dagan R, Ashur Y, et al. Interference of antibody production to hepatitis B surface antigen in a combination hepatitis A/hepatitis B vaccine. J Infect Dis. Dec. 1999;180(6):2018-22. Not eligible target population. [pmid: 10558961].
140 Fried MW, Fong TL, Swain MG, et al. Therapy of chronic hepatitis B with a 6-month course of ribavirin. J Hepatol. Aug. 1994;21(2):145-50. Unapproved itnervention. [pmid: 7989704].
141 Fukuhara M, Matsumura K, Ohmori S, et al. Effects of interferon on circadian changes in blood pressure and heart rate variability in patients with chronic hepatitis. Am J Hypertens. May. 1999;12(5):519-23. Not eligible outcomes. [pmid: 10342791].
142 Gaia S, Marzano A, Smedile A, et al. Four years of treatment with lamivudine: clinical and virological evaluations in HBe antigen-negative chronic hepatitis B. Aliment Pharmacol Ther. Aug 1. 2004;20(3):281-7. No associative hypothesis tested. [pmid: 15274664].
143 Galban-Garcia E, Vega-Sanchez H, Gra-Oramas B, et al. Efficacy of ribavirin in patients with chronic hepatitis B. J Gastroenterol. 2000;35(5):347-52. Unapproved itnervention. [pmid: 10832669].
144 Galsky J, Bansky G, Holubova T, et al. Effect of ursodeoxycholic acid in acute viral hepatitis. J Clin Gastroenterol. Apr. 1999;28(3):249-53. Not eligible target population. [pmid: 10192613].
145 Gayraud M, Guillevin L, le Toumelin P, et al. Long-term followup of polyarteritis nodosa, microscopic polyangiitis, and Churg-Strauss syndrome: analysis of four prospective trials including 278 patients. Arthritis Rheum. Mar. 2001;44(3):666-75. Not eligible target population. [pmid: 11263782].
146 Gellin BG, Greenberg RN, Hart RH, et al. Immunogenicity of two doses of yeast recombinant hepatitis B vaccine in healthy older adults. J Infect Dis. Jun. 1997;175(6):1494-7. Not eligible target population. [pmid: 9180192].
147 Genereau T, Lortholary O, Leclerq P, et al. Treatment of systemic vasculitis with cyclophosphamide and steroids: daily oral low-dose cyclophosphamide administration after failure of a pulse intravenous high-dose regimen in four patients. Br J Rheumatol. Oct. 1994;33(10):959-62. Not eligible target population. [pmid: 7921758].
148 Ghabouli MJ, Sabouri AH, Shoeibi N, et al. High seroprotection rate induced by intradermal administration of a recombinant hepatitis B vaccine in young healthy adults: comparison with standard intramuscular vaccination. Eur J Epidemiol. 2004;19(9):871-5. Not eligible target population. [pmid: 15499897].
149 Gilson RJ, Chopra KB, Newell AM, et al. A placebo-controlled phase I/II study of adefovir dipivoxil in patients with chronic hepatitis B virus infection. J Viral Hepat. Sep. 1999;6(5):387-95. Small sample size. [pmid: 10607255].
150 Gish RG, Trinh H, Leung N, et al. Safety and antiviral activity of emtricitabine (FTC) for the treatment of chronic hepatitis B infection: a two-year study. J Hepatol. Jul. 2005;43(1):60-6. Unapproved itnervention. [pmid: 15922478].
151 Gisolf EH, Dreezen C, Danner SA, et al. Risk factors for hepatotoxicity in HIV-1-infected patients receiving ritonavir and saquinavir with or without stavudine. Prometheus Study Group. Clin Infect Dis. Nov. 2000;31(5):1234-9. Not eligible target population. [pmid: 11073757].
152 Giustina G, Fattovich G, De Paoli M, et al. Serum procollagen type III peptide in chronic hepatitis B. Relationship to disease activity and response to interferon-alpha therapy. Int J Clin Lab Res. 1996;26(1):33-6. Case-series. [pmid: 8739853].
153 Gizaris V, Roumeliotou A, Ktenas E, et al. Evaluation of the immunogenicity of a recombinant vaccine against hepatitis B containing S and pre-S2 sequences using two different schedules. Vaccine. Nov. 1993;11(14):1445-7. Not eligible target population. [pmid: 8310765].
154 Goldwater PN. Randomized comparative trial of interferon-alpha versus placebo in hepatitis B vaccine non-responders and hyporesponders. Vaccine. Apr. 1994;12(5):410-4. Not eligible target population. [pmid: 8023548].
155 Goldwater PN. Randomized, comparative trial of 20 micrograms vs 40 micrograms Engerix B vaccine in hepatitis B vaccine non-responders. Vaccine. Mar. 1997;15(4):353-6. Not eligible target population. [pmid: 9141204].
156 Goldwater PN. A pilot study of SRL 172 (killed Mycobacterium vaccae) in healthy chronic hepatitis B carriers and hepatitis B vaccine non-responders. Hum Vaccin. Jan–Feb. 2006;2(1):8-13. Not eligible target population. [pmid: 17012900].
157 Goncalez TT, Sabino EC, Murphy EL, et al. Human immunodeficiency virus test-seeking motivation in blood donors, Sao Paulo, Brazil. Vox Sang. Apr. 2006;90(3):170-6. Not eligible target population. [pmid: 16507016].
158 Gonzalez ML, Usandizaga M, Alomar P, et al. Intradermal and intramuscular route for vaccination against hepatitis B. Vaccine. Aug. 1990;8(4):402-5. Not eligible target population. [pmid: 2144391].
159 Gonzalez-Mateos F, Garcia-Monzon C, Garcia-Buey L, et al. Long-term effect of interferon alpha alone or after prednisone withdrawal in chronic hepatitis B. Interim report and review of the literature. Hepatogastroenterology. Nov–Dec. 1995;42(6):893-9. Small sample size. [pmid: 8847042].
160 Gorka W, Gorka TS, Lewall DB. Doppler ultrasound evaluation of advanced portal vein pulsatility in patients with normal echocardiograms. Eur J Ultrasound. Nov. 1998;8(2):119-23. Not eligible target population. [pmid: 9845793].
161 Gow PJ, Mutimer DJ. De novo hepatitis B infection acquired during liver transplantation. QJM. May. 2001;94(5):271-5. Not eligible target population. [pmid: 11353102].
162 Green MS, Cohen D, Lerman Y, et al. Depression of the immune response to an inactivated hepatitis A vaccine administered concomitantly with immune globulin. J Infect Dis. Sep. 1993;168(3):740-3. Not eligible target population. [pmid: 8394864].
163 Green MS, Cohen D, Lerman Y, et al. A trial of the reactogenicity and immunogenicity of an inactivated hepatitis A vaccine. Isr J Med Sci. May–Jun. 1994;30(56):485-8. Not eligible target population. [pmid: 8034508].
164 Greub G, Genton B, Safary A, et al. Comparison of the reactogenicity and immunogenicity of a two injection combined high-dose hepatitis A and hepatitis B vaccine to those of Twinrix. Vaccine. Dec 8. 2000;19(910):1113-7. Not eligible target population. [pmid: 11137246].
165 Grosheide PM, del Canho R, Heijtink RA, et al. Passive-active immunization in infants of hepatitis Be antigen-positive mothers. Comparison of the efficacy of early and delayed active immunization. Am J Dis Child. Dec. 1993;147(12):1316-20. Not eligible target population. [pmid: 8249953].
166 Guan R, Yeoh KG, Yap I, et al. Subcutaneously administered recombinant human beta-interferon in the treatment of chronic hepatitis B virus infection. Aliment Pharmacol Ther. Oct. 1996;10(5):807-14. Unapproved itnervention. [pmid: 8899091].
167 Guillevin L. Treatment of polyarteritis nodosa and Churg-Strauss angiitis: indications of plasma exchange. Results of three prospective trials in 162 patients. The Cooperative Study Group for the Study of Polyarteritis Nodosa. Prog Clin Biol Res. 1990;337:309-17. Not eligible target population. [pmid: 1972283].
168 Guillevin L, Fain O, Lhote F, et al. Lack of superiority of steroids plus plasma exchange to steroids alone in the treatment of polyarteritis nodosa and Churg-Strauss syndrome. A prospective, randomized trial in 78 patients. Arthritis Rheum. Feb. 1992;35(2):208-15. Not eligible target population. [pmid: 1346499].
169 Guillevin L, Lhote F. Treatment of polyarteritis nodosa and Churg-Strauss syndrome: indications of plasma exchanges. Transfus Sci. Dec. 1994;15(4):371-88. Not eligible target population. [pmid: 10155556].
170 Guillevin L, Lhote F, Cohen P, et al. Corticosteroids plus pulse cyclophosphamide and plasma exchanges versus corticosteroids plus pulse cyclophosphamide alone in the treatment of polyarteritis nodosa and Churg-Strauss syndrome patients with factors predicting poor prognosis. A prospective, randomized trial in sixty-two patients. Arthritis Rheum. Nov. 1995;38(11):1638-45. Not eligible target population. [pmid: 7488285].
171 Guillevin L, Lhote F, Jarrousse B, et al. Treatment of polyarteritis nodosa and Churg-Strauss syndrome. A meta-analysis of 3 prospective controlled trials including 182 patients over 12 years. Ann Med Interne (Paris). 1992;143(6):405-16. Secondary data analysis. [pmid: 1363508].
172 Gunsar F, Akarca US, Ersoz G, et al. Two-year interferon therapy with or without ribavirin in chronic delta hepatitis. Antivir Ther. 2005;10(6):721-6. Not eligible target population. [pmid: 16218171].
173 Guptan RC, Thakur V, Kazim SN, et al. Efficacy of granulocyte-macrophage colony-stimulating factor or lamivudine combination with recombinant interferon in non-responders to interferon in hepatitis B virus-related chronic liver disease patients. J Gastroenterol Hepatol. Jul. 2002;17(7):765-71. Unapproved itnervention. [pmid: 12121506].
174 Guptan RC, Thakur V, Malhotra V, et al. Low-dose recombinant interferon therapy in anti-HBe-positive chronic hepatitis B in Asian Indians. J Gastroenterol Hepatol. Jul. 1998;13(7):675-9. Not controlled not randomized clinical trial. [pmid: 9715416].
175 Guptan RC, Thakur V, Raina V, et al. Alpha-interferon therapy in chronic hepatitis due to active dual infection with hepatitis B and C viruses. J Gastroenterol Hepatol. Sep. 1999;14(9):893-8. Case-series. [pmid: 10535471].
176 Hadziyannis S, Alexopoulou A, Papakonstantinou A, et al. Interferon treatment with or without oral ganciclovir in HBeAg-negative chronic hepatitis B: a randomized study. J Viral Hepat. May. 2000;7(3):235-40. Unapproved itnervention. [pmid: 10849267].
177 Hadziyannis SJ, Manesis EK, Papakonstantinou A. Oral ganciclovir treatment in chronic hepatitis B virus infection: a pilot study. J Hepatol. Aug. 1999;31(2):210-4. Unapproved itnervention.
178 Hahm KB, Han KY, Kim WH, et al. Efficacy of polyadenylic.polyuridylic acid in the treatment of chronic active hepatitis B. Int J Immunopharmacol. Mar. 1994;16(3):217-25. Not eligible exposure. [pmid: 8206687].
179 Halliday ML, Rankin JG, Bristow NJ, et al. A randomized double-blind clinical trial of a mammalian cell-derived recombinant DNA hepatitis B vaccine compared with a plasma-derived vaccine. Arch Intern Med. Jun. 1990;150(6):1195-200. Not eligible target population. [pmid: 2141247].
180 Halperin SA, Dobson S, McNeil S, et al. Comparison of the safety and immunogenicity of hepatitis B virus surface antigen co-administered with an immunostimulatory phosphorothioate oligonucleotide and a licensed hepatitis B vaccine in healthy young adults. Vaccine. Jan 9. 2006;24(1):20-6. Not eligible target population. [pmid: 16198027].
181 Halperin SA, Van Nest G, Smith B, et al. A phase I study of the safety and immunogenicity of recombinant hepatitis B surface antigen co-administered with an immunostimulatory phosphorothioate oligonucleotide adjuvant. Vaccine. Jun 2. 2003;21(1920):2461-7. Not eligible target population. [pmid: 12744879].
182 Hammond GW, Parker J, Mimms L, et al. Comparison of immunogenicity of two yeast-derived recombinant hepatitis B vaccines. Vaccine. Feb. 1991;9(2):97-100. Not eligible target population. [pmid: 1829306].
183 Han YX, Xue R, Zhao W, et al. Antiviral therapeutic efficacy of foscarnet in hepatitis B virus infection. Antiviral Res. Dec. 2005;68(3):147-53. Unapproved itnervention. [pmid: 16280177].
184 Hasan F, al-Khaldi J, Asker H, et al. Treatment of chronic hepatitis B with the sequential administration of interferon and lamivudine. Hepatogastroenterology. Nov–Dec. 2003;50(54):2040-2. Unapproved itnervention. [pmid: 14696461].
185 Hasan MS, Agosti JM, Reynolds KK, et al. Granulocyte macrophage colony-stimulating factor as an adjuvant for hepatitis B vaccination of healthy adults. J Infect Dis. Dec. 1999;180(6):2023-6. Not eligible target population. [pmid: 10558962].
186 Heineman TC, Clements-Mann ML, Poland GA, et al. A randomized, controlled study in adults of the immunogenicity of a novel hepatitis B vaccine containing MF59 adjuvant. Vaccine. Jul 16. 1999;17(22):2769-78. Not eligible target population. [pmid: 10438046].
187 Henderson EA, Louie TJ, Ramotar K, et al. Comparison of higher-dose intradermal hepatitis B vaccination to standard intramuscular vaccination of healthcare workers. Infect Control Hosp Epidemiol. Apr. 2000;21(4):264-9. Not eligible target population. [pmid: 10782589].
188 Hislop TG, Teh C, Low A, et al. Predisposing, reinforcing and enabling factors associated with hepatitis B testing in Chinese Canadians in British Columbia. Asian Pac J Cancer Prev. Jan–Mar. 2007;8(1):39-44. Not eligible target population. [pmid: 17477769].
189 Hohler T, Stradmann-Bellinghausen B, Starke R, et al. C4A deficiency and nonresponse to hepatitis B vaccination. J Hepatol. Sep. 2002;37(3):387-92. Not eligible target population. [pmid: 12175635].
190 Honkoop P, de Man RA, Zondervan PE, et al. Histological improvement in patients with chronic hepatitis B virus infection treated with lamivudine. Liver. Apr. 1997;17(2):103-6. Small sample size. [pmid: 9138281].
191 Hope RL, Weltman M, Dingley J, et al. Interferon alfa for chronic active hepatitis B. Long term follow-up of 62 patients: outcomes and predictors of response. Med J Aust. Jan 2. 1995;162(1):8-11. Unapproved itnervention. [pmid: 7845310].
192 Huang J, Jiang D, Wang X, et al. Changing knowledge, behavior, and practice related to universal precautions among hospital nurses in China. J Contin Educ Nurs. Sep–Oct. 2002;33(5):217-24. Not eligible target population. [pmid: 12269760].
193 Huang YH, Wu JC, Chang TT, et al. Analysis of clinical, biochemical and viral factors associated with early relapse after lamivudine treatment for hepatitis B e antigen-negative chronic hepatitis B patients in Taiwan. J Viral Hepat. Jul. 2003;10(4):277-84. Case-series. [pmid: 12823594].
194 Huang ZM, Huang QW, Qin YQ, et al. YMDD mutations in patients with chronic hepatitis B untreated with antiviral medicines. World J Gastroenterol. Feb 14. 2005;11(6):867-70. Case-series. [pmid: 15682483].
195 Hui CK, Lai LS, Lam P, et al. 48 weeks pegylated interferon alpha-2a is superior to 24 weeks of pegylated interferon alpha-2b in achieving hepatitis B e antigen seroconversion in chronic hepatitis B infection. Aliment Pharmacol Ther. Apr 15. 2006;23(8):1171-8. Not eligible exposure. [pmid: 16611278].
196 Iino S, Toyota J, Kumada H, et al. The efficacy and safety of thymosin alpha-1 in Japanese patients with chronic hepatitis B; results from a randomized clinical trial. J Viral Hepat. May. 2005;12(3):300-6. Unapproved itnervention. [pmid: 15850471].
197 Iorio R, Giannattasio A, Cirillo F, et al. Long-term outcome in children with chronic hepatitis B: a 24-year observation period. Clin Infect Dis. Oct 15. 2007;45(8):943-9. Not eligible target population. [pmid: 17879906].
198 Israeli E, Safadi R, Melhem A, et al. Induction of oral immune regulation towards liver-extracted proteins for treatment of chronic HBV and HCV hepatitis: results of a phase I clinical trial. Liver Int. Aug. 2004;24(4):295-307. Case-series. [pmid: 15287852].
199 Jackson JC, Rhodes LA, Inui TS, et al. Hepatitis B among the Khmer. Issues of translation and concepts of illness. J Gen Intern Med. May. 1997;12(5):292-8. Not eligible target population. [pmid: 9159698].
200 Jackson KM, Steele TF, Dugan EP, et al. Effect of lymphatic and splenic pump techniques on the antibody response to hepatitis B vaccine: a pilot study. J Am Osteopath Assoc. Mar. 1998;98(3):155-60. Not eligible target population. [pmid: 9558831].
201 Jacobson LP, Zhang BC, Zhu YR, et al. Oltipraz chemoprevention trial in Qidong, People's Republic of China: study design and clinical outcomes. Cancer Epidemiol Biomarkers Prev. Apr. 1997;6(4):257-65. Not eligible outcomes. [pmid: 9107431].
202 Jacques P, Moens G, Desombere I, et al. The immunogenicity and reactogenicity profile of a candidate hepatitis B vaccine in an adult vaccine non-responder population. Vaccine. Nov 1. 2002;20(3132):3644-9. Not eligible target population. [pmid: 12399191].
203 Jang JW, Bae SH, Choi JY, et al. Early virological response predicts outcome during extended lamivudine retreatment in patients with chronic hepatitis B who relapsed after initial HBeAg responses. J Gastroenterol Hepatol. Feb. 2006;21(2):384-91. Not eligible outcomes. [pmid: 16509863].
204 Jang JW, Choi JY, Bae SH, et al. A randomized controlled study of preemptive lamivudine in patients receiving transarterial chemo-lipiodolization. Hepatology. Feb. 2006;43(2):233-40. Not eligible exposure. [pmid: 16440357].
205 Janssen HL, Berk L, Heijtink RA, et al. Interferon-alpha and zidovudine combination therapy for chronic hepatitis B: results of a randomized, placebo-controlled trial. Hepatology. Mar. 1993;17(3):383-8. Unapproved itnervention. [pmid: 8444411].
206 Jelic S, Kovcin V, Milanovic N, et al. Randomized study of zorubicin versus zorubicin-cisplatin in undifferentiated carcinoma of the nasopharynx (UCNT). Ann Oncol. Aug. 1997;8(8):739-44. Not eligible target population. [pmid: 9332680].
207 Joines RW, Blatter M, Abraham B, et al. A prospective, randomized, comparative US trial of a combination hepatitis A and B vaccine (Twinrix) with corresponding monovalent vaccines (Havrix and Engerix-B) in adults. Vaccine. Sep 14. 2001;19(32):4710-9. Not eligible target population. [pmid: 11535321].
208 Joshi N, Kumar A, Sreenivas DV, et al. Safety and immunogenicity of indigenous recombinant hepatitis B vaccine (Shanvac-B) in comparison with commercially available vaccine. Indian J Gastroenterol. Apr–Jun. 2000;19(2):71-3. Not eligible target population. [pmid: 10812819].
209 Jung MC, Gruner N, Zachoval R, et al. Immunological monitoring during therapeutic vaccination as a prerequisite for the design of new effective therapies: induction of a vaccine-specific CD4+ T-cell proliferative response in chronic hepatitis B carriers. Vaccine. Oct 4. 2002;20(2930):3598-612. Not eligible exposure. [pmid: 12297407].
210 Jungers P, Chauveau P, Courouce AM, et al. Immunogenicity of the recombinant GenHevac B Pasteur vaccine against hepatitis B in chronic uremic patients. J Infect Dis. Feb. 1994;169(2):399-402. Not eligible target population. [pmid: 8106774].
211 Jungers P, Devillier P, Salomon H, et al. Randomised placebo-controlled trial of recombinant interleukin-2 in chronic uraemic patients who are non-responders to hepatitis B vaccine. Lancet. Sep 24. 1994;344(8926):856-7. Not eligible target population. [pmid: 7916403].
212 Jurim O, Martin P, Winston DJ, et al. Failure of ganciclovir prophylaxis to prevent allograft reinfection following orthotopic liver transplantation for chronic hepatitis B infection. Liver Transpl Surg. Sep. 1996;2(5):370-4. Not eligible target population. [pmid: 9346678].
213 Kakizaki S, Sohara N, Sato K, et al. Preventive effects of vitamin K on recurrent disease in patients with hepatocellular carcinoma arising from hepatitis C viral infection. J Gastroenterol Hepatol. Apr. 2007;22(4):518-22. Not eligible target population. [pmid: 17376044].
214 Kakumu S, Ishikawa T, Mizokami M, et al. Treatment with human gamma interferon of chronic hepatitis B: comparative study with alpha interferon. J Med Virol. Sep. 1991;35(1):32-7. Unapproved itnervention. [pmid: 1940881].
215 Kakumu S, Yoshioka K, Wakita T, et al. Pilot study of ribavirin and interferon-beta for chronic hepatitis B. Hepatology. Aug. 1993;18(2):258-63. Unapproved itnervention. [pmid: 8340055].
216 Kanematsu M, Semelka RC, Matsuo M, et al. Gadolinium-enhanced MR imaging of the liver: optimizing imaging delay for hepatic arterial and portal venous phases—a prospective randomized study in patients with chronic liver damage. Radiology. Nov. 2002;225(2):407-15. Not eligible exposure. [pmid: 12409573].
217 Kapicioglu S, Sari M, Kaynar K, et al. The effect of indomethacin on hepatitis B virus replication in chronic healthy carriers. Scand J Gastroenterol. Sep. 2000;35(9):957-9. Not eligible exposure. [pmid: 11063156].
218 Kappelhoff BS, van Leth F, MacGregor TR, et al. Nevirapine and efavirenz pharmacokinetics and covariate analysis in the 2NN study. Antivir Ther. 2005;10(1):145-55. Not eligible target population. [pmid: 15751772].
219 Karabay O, Tamer A, Tahtaci M, et al. Effectiveness of lamivudine and interferon-alpha combination therapy versus interferon-alpha monotherapy for the treatment of HBeAg-negative chronic hepatitis B patients: a randomized clinical trial. J Microbiol Immunol Infect. Aug. 2005;38(4):262-6. Unapproved itnervention. [pmid: 16118673].
220 Katiyar CK, Arora D, Mehrotra R, et al. Management of chronic hepatitis B with New Livfit in end stage renal disease. Indian J Physiol Pharmacol. Jan. 2005;49(1):83-8. Not eligible exposure. [pmid: 15881863].
221 Katkov WN, Watkins E, DeMelia HC, et al. Immunogenicity of a ‘pre-S2 plus S’ hepatitis B vaccine in healthy adults. J Viral Hepat. 1994;1(1):79-83. Not eligible target population. [pmid: 8790563].
222 Kayatas M. Levamisole treatment enhances protective antibody response to hepatitis B vaccination in hemodialysis patients. Artif Organs. Jun. 2002;26(6):492-6. Not eligible target population. [pmid: 12072104].
223 Kaymakoglu S, Danalioglu A, Demir K, et al. Long-term results of interferon alpha monotherapy in patients with HBeAg-negative chronic hepatitis B. Dig Dis Sci. Mar. 2007;52(3):727-31. Case-series. [pmid: 17237999].
224 Keefer MC, Bonnez W, Roberts NJ Jr, et al. Human immunodeficiency virus (HIV-1) gp160-specific lymphocyte proliferative responses of mononuclear leukocytes from HIV-1 recombinant gp160 vaccine recipients. J Infect Dis. Mar. 1991;163(3):448-53. Not eligible target population. [pmid: 1995718].
225 Keitel WA, Kester KE, Atmar RL, et al. Phase I trial of two recombinant vaccines containing the 19kd carboxy terminal fragment of Plasmodium falciparum merozoite surface protein 1 (msp-1(19)) and T helper epitopes of tetanus toxoid. Vaccine. Oct 14. 1999;18(56):531-9. Not eligible target population. [pmid: 10519944].
226 Kim MJ, Nafziger AN, Harro CD, et al. Revaccination of healthy nonresponders with hepatitis B vaccine and prediction of seroprotection response. Vaccine. Mar 7. 2003;21(1112):1174-9. Not eligible target population. [pmid: 12559795].
227 Koryem HK, Taha KM, Ibrahim IK, et al. Liver toxicity profile in gold-treated Egyptian rheumatoid arthritis patients. Int J Clin Pharmacol Res. 1998;18(1):31-7. Not eligible target population. [pmid: 9604732].
228 Krishnamurthy K, John GT, Abraham P, et al. Granulocyte macrophage colony stimulating factor augmented hepatitis B vaccine protocol for rapid seroprotection in voluntary kidney donors. Indian J Med Res. Apr. 2004;119(4):162-4. Not eligible target population. [pmid: 15147122].
229 Krogsgaard K. The long-term effect of treatment with interferon-alpha 2a in chronic hepatitis B. The Long-Term Follow-up Investigator Group. The European Study Group on Viral Hepatitis (EUROHEP). Executive Team on Anti-Viral Treatment. J Viral Hepat. Nov. 1998;5(6):389-97. Unapproved itnervention. [pmid: 9857348].
230 Krogsgaard K, Marcellin P, Trepo C, et al. Prednisolone withdrawal therapy enhances the effect of human lymphoblastoid interferon in chronic hepatitis B. INTERPRED Trial Group. J Hepatol. Dec. 1996;25(6):803-13. Unapproved itnervention. [pmid: 9007706].
231 Kumar M, Satapathy S, Monga R, et al. A randomized controlled trial of lamivudine to treat acute hepatitis B. Hepatology. Jan. 2007;45(1):97-101. Not eligible target population. [pmid: 17187417].
232 Kundig TM, Senti G, Schnetzler G, et al. Der p 1 peptide on virus-like particles is safe and highly immunogenic in healthy adults. J Allergy Clin Immunol. Jun. 2006;117(6):1470-6. Not eligible target population. [pmid: 16751015].
233 Kundu SS, Kundu AK, Pal NK. Interferon-alpha in the treatment of acute prolonged hepatitis B virus infection. J Assoc Physicians India. Jul. 2000;48(7):671-3. Not eligible target population. [pmid: 11273498].
234 Kung AW, Jones BM, Lai CL. Effects of interferon-gamma therapy on thyroid function, T-lymphocyte subpopulations and induction of autoantibodies. J Clin Endocrinol Metab. Nov. 1990;71(5):1230-4. Not eligible exposure. [pmid: 2121769].
235 Lai CL, Ching CK, Tung AK, et al. Lamivudine is effective in suppressing hepatitis B virus DNA in Chinese hepatitis B surface antigen carriers: a placebo-controlled trial. Hepatology. Jan. 1997;25(1):241-4. Small sample size. [pmid: 8985298].
236 Lai CL, Lim SG, Brown NA, et al. A dose-finding study of once-daily oral telbivudine in HBeAg-positive patients with chronic hepatitis B virus infection. Hepatology. Sep. 2004;40(3):719-26. Small sample size. [pmid: 15349912].
237 Lai CL, Yuen MF, Hui CK, et al. Comparison of the efficacy of lamivudine and famciclovir in Asian patients with chronic hepatitis B: results of 24 weeks of therapy. J Med Virol. Jul. 2002;67(3):334-8. Unapproved itnervention. [pmid: 12116023].
238 Lambert JS, Viscidi R, Walker MC, et al. Antibody to human immunodeficiency virus type 1 (HIV-1) gp160 in mucosal specimens of asymptomatic HIV-1-infected volunteers parenterally immunized with an experimental recombinant HIV-1 IIIB gp160 vaccine. The National Institute of Allergy and Infectious Diseases-sponsored AIDS Vaccine Evaluation Group. Clin Diagn Lab Immunol. May. 1997;4(3):302-8. Not eligible target population. [pmid: 9144368].
239 Lampertico P, Manzin A, Rumi MG, et al. Hepatitis B virus precore mutants in HBeAg carriers with chronic hepatitis treated with interferon. J Viral Hepat. 1995;2(5):251-6. Unapproved itnervention. [pmid: 8745317].
240 Laskus T, Rakela J, Persing DH. Nucleotide sequence analysis of precore and proximal core regions in patients with chronic hepatitis B treated with interferon. Dig Dis Sci. Jan. 1995;40(1):1-7. Unapproved itnervention. [pmid: 7821093].
241 Lau DT, Everhart J, Kleiner DE, et al. Long-term follow-up of patients with chronic hepatitis B treated with interferon alfa. Gastroenterology. Nov. 1997;113(5):1660-7. Seconday data analysis. [pmid: 9352870].
242 Lau GK, Tsiang M, Hou J, et al. Combination therapy with lamivudine and famciclovir for chronic hepatitis B-infected Chinese patients: a viral dynamics study. Hepatology. Aug. 2000;32(2):394-9. Unapproved itnervention. [pmid: 10915748].
243 Lau GK, Yiu HH, Fong DY, et al. Early is superior to deferred preemptive lamivudine therapy for hepatitis B patients undergoing chemotherapy. Gastroenterology. Dec. 2003;125(6):1742-9. Not eligible target population. [pmid: 14724827].
244 Lau JY, King R, Tibbs CJ, et al. Loss of HBsAg with interferon-alpha therapy in chronic hepatitis D virus infection. J Med Virol. Apr. 1993;39(4):292-6. Not eligible target population. [pmid: 8492101].
245 Lau JY, Lai CL, Wu PC, et al. A randomised controlled trial of recombinant interferon-gamma in Chinese patients with chronic hepatitis B virus infection. J Med Virol. Jul. 1991;34(3):184-7. Not eligible exposure. [pmid: 1919540].
246 Laube I, Boehler A, Renner EL, et al. Valaciclovir for chronic hepatitis B virus infection after lung transplantation. Infection. Feb. 2004;32(1):51-3. Case Reports. [pmid: 15007743].
247 Lausten SB, Ibrahim TM, El-Sefi T, et al. Systemic and cell-mediated immune response after laparoscopic and open cholecystectomy in patients with chronic liver disease. A randomized, prospective study. Dig Surg. 1999;16(6):471-7. Not eligible target population. [pmid: 10805546].
248 Law WP, Duncombe CJ, Mahanontharit A, et al. Impact of viral hepatitis co-infection on response to antiretroviral therapy and HIV disease progression in the HIV-NAT cohort. AIDS. May 21. 2004;18(8):1169-77. Not eligible target population. [pmid: 15166532].
249 Lee FY, Tsai YT, Lin HC, et al. Hemodynamic effects of a combination of vasopressin and ketanserin in patients with hepatitis b-related cirrhosis. J Hepatol. May. 1992;15(12):54-8. Not eligible exposure. [pmid: 1506656].
250 Lee HS, Chung YH, Lee K, et al. A 12-week clevudine therapy showed potent and durable antiviral activity in HBeAg-positive chronic hepatitis B. Hepatology. May. 2006;43(5):982-8. Unapproved itnervention. [pmid: 16628625].
251 Lee KW, Lee SK, Joh JW, et al. Comparison of the efficacy in prevention of hepatitis B virus recurrence after liver transplantation between HBIG and lamivudine. Transplant Proc. Nov–Dec. 2001;33(78):3643-4. Not eligible target population. [pmid: 11750547].
252 Lee SD, Chan CY, Yu MI, et al. A two dose combined hepatitis A and B vaccine in Chinese youngsters. J Med Virol. Sep. 1999;59(1):1-4. Not eligible target population. [pmid: 10440800].
253 Lee SD, Tong MJ, Wu JC, et al. A randomised double-blind placebo-controlled trial of prednisolone therapy in HBeAg and HBV DNA positive Chinese patients with chronic active hepatitis B. J Hepatol. Mar. 1991;12(2):246-50. Not eligible exposure. [pmid: 2051004].
254 Lee SU, Choi KH, Ha BJ, et al. Effect of adenine arabinoside and alpha-interferon in patients with HBeAg-positive chronic active hepatitis. Korean J Intern Med. Jan. 1990;5(1):1-4. Not eligible exposure. [pmid: 2271507].
255 Leemans WF, Flink HJ, Janssen HL, et al. The effect of pegylated interferon-alpha on the treatment of lamivudine resistant chronic HBeAg positive hepatitis B virus infection. J Hepatol. Mar. 2006;44(3):507-11. Case-series. [pmid: 16457904].
256 Leroux-Roels G, Desombere I, Cobbaut L, et al. Hepatitis B vaccine containing surface antigen and selected preS1 and preS2 sequences. 2. Immunogenicity in poor responders to hepatitis B vaccines. Vaccine. Nov. 1997;15(16):1732-6. Not eligible target population. [pmid: 9364675].
257 Leroux-Roels G, Desombere I, De Tollenaere G, et al. Hepatitis B vaccine containing surface antigen and selected preS1 and preS2 sequences. 1. Safety and immunogenicity in young, healthy adults. Vaccine. Nov. 1997;15(16):1724-31. Not eligible target population. [pmid: 9364674].
258 Leroux-Roels G, Moreau W, Desombere I, et al. Safety and immunogenicity of a combined hepatitis A and hepatitis B vaccine in young healthy adults. Scand J Gastroenterol. Oct. 1996;31(10):1027-31. Not eligible target population. [pmid: 8898425].
259 Leroux-Roels G, Van Hecke E, Michielsen W, et al. Correlation between in vivo humoral and in vitro cellular immune responses following immunization with hepatitis B surface antigen (HBsAg) vaccines. Vaccine. Jul. 1994;12(9):812-8. Not eligible target population. [pmid: 7975860].
260 Levie K, Gjorup I, Skinhoj P, et al. A 2-dose regimen of a recombinant hepatitis B vaccine with the immune stimulant AS04 compared with the standard 3-dose regimen of Engerix-B in healthy young adults. Scand J Infect Dis. 2002;34(8):610-4. Not eligible target population. [pmid: 12238579].
261 Levy G, Burra P, Cavallari A, et al. Improved clinical outcomes for liver transplant recipients using cyclosporine monitoring based on 2-hr post-dose levels (C2). Transplantation. Mar 27. 2002;73(6):953-9. Not eligible target population. [pmid: 11923699].
262 Li W, Wang C, Zhang J. Effects of da ding feng zhu decoction in 30 cases of liver fibrosis. J Tradit Chin Med. Dec. 2003;23(4):251-4. Not eligible exposure. [pmid: 14719288].
263 Liaw YF, Lin SM, Chen TJ, et al. Beneficial effect of prednisolone withdrawal followed by human lymphoblastoid interferon on the treatment of chronic type B hepatitis in Asians: a randomized controlled trial. J Hepatol. Feb. 1994;20(2):175-80. Unapproved itnervention. [pmid: 8006397].
264 Lim MJ, Kwon SR, Lee S, et al. Rapid improvement of distal vasculitis in PAN related to hepatitis B with alprostadil infusion: a case report. Rheumatol Int. Aug. 2006;26(10):928-32. Case Reports. [pmid: 16435120].
265 Lim SG, Krastev Z, Ng TM, et al. Randomized, double-blind study of emtricitabine (FTC) plus clevudine versus FTC alone in treatment of chronic hepatitis B. Antimicrob Agents Chemother. May. 2006;50(5):1642-8. Unapproved itnervention. [pmid: 16641430].
266 Lim SG, Ng TM, Kung N, et al. A double-blind placebo-controlled study of emtricitabine in chronic hepatitis B. Arch Intern Med. Jan 9. 2006;166(1):49-56. Unapproved itnervention. [pmid: 16401810].
267 Lim SG, Wai CT, Lee YM, et al. A randomized, placebo-controlled trial of thymosin-alpha1 and lymphoblastoid interferon for HBeAg-positive chronic hepatitis B. Antivir Ther. 2006;11(2):245-53. Unapproved itnervention. [pmid: 16640105].
268 Lin DY, Sheen IS, Chu CM, et al. A prospective randomized trial of colchicine in prevention of liver cirrhosis in chronic hepatitis B patients. Aliment Pharmacol Ther. Dec. 1996;10(6):961-6. Not eligible exposure. [pmid: 8971295].
269 Lin HC, Hou MC, Lee WC, et al. Effects of octreotide on central hemodynamics and systemic oxygen use in patients with viral cirrhosis. Am J Gastroenterol. Apr. 1999;94(4):1012-7. Not eligible exposure. [pmid: 10201475].
270 Lin HC, Tsai YT, Huang CC, et al. Effects of octreotide on postprandial systemic and hepatic hemodynamics in patients with postnecrotic cirrhosis. J Hepatol. Sep. 1994;21(3):424-9. Not eligible exposure. [pmid: 7836713].
271 Lin HC, Yang YY, Hou MC, et al. Hemodynamic effects of a combination of octreotide and terlipressin in patients with viral hepatitis related cirrhosis. Scand J Gastroenterol. Apr. 2002;37(4):482-7. Not eligible exposure. [pmid: 11989841].
272 Lin SM, Sheen IS, Chien RN, et al. Long-term beneficial effect of interferon therapy in patients with chronic hepatitis B virus infection. Hepatology. Mar. 1999;29(3):971-5. Unapproved itnervention. [pmid: 10051505].
273 Lin SM, Tai DI, Chien RN, et al. Comparison of long-term effects of lymphoblastoid interferon alpha and recombinant interferon alpha-2a therapy in patients with chronic hepatitis B. J Viral Hepat. Jul. 2004;11(4):349-57. Unapproved itnervention. [pmid: 15230858].
274 Liu CJ, Lai MY, Chao YC, et al. Interferon alpha-2b with and without ribavirin in the treatment of hepatitis B e antigen-positive chronic hepatitis B: a randomized study. Hepatology. Apr. 2006;43(4):742-9. Unapproved itnervention. [pmid: 16557544].
275 Liu CL, Fan ST, Lo CM, et al. Abdominal drainage after hepatic resection is contraindicated in patients with chronic liver diseases. Ann Surg. Feb. 2004;239(2):194-201. Not eligible exposure. [pmid: 14745327].
276 Liu P, Hu YY, Liu C, et al. Multicenter clinical study on Fuzhenghuayu capsule against liver fibrosis due to chronic hepatitis B. World J Gastroenterol. May 21. 2005;11(19):2892-9. Not eligible exposure. [pmid: 15902724].
277 Liu P, Hu YY, Liu C, et al. Clinical observation of salvianolic acid B in treatment of liver fibrosis in chronic hepatitis B. World J Gastroenterol. Aug. 2002;8(4):679-85. Not eligible exposure. [pmid: 12174378].
278 Lo CM, Liu CL, Chan SC, et al. A randomized, controlled trial of postoperative adjuvant interferon therapy after resection of hepatocellular carcinoma. Ann Surg. Jun. 2007;245(6):831-42. Not eligible target population. [pmid: 17522506].
279 Lo CM, Liu CL, Chan SC, et al. Failure of hepatitis B vaccination in patients receiving lamivudine prophylaxis after liver transplantation for chronic hepatitis B. J Hepatol. Aug. 2005;43(2):283-7. Not eligible target population. [pmid: 15964658].
280 Lok AS. Alpha-interferon therapy for chronic hepatitis B virus infection in children and Oriental patients. J Gastroenterol Hepatol. 1991;6(Suppl 1):15-7. Review. [pmid: 1751798].
281 Lok AS, Lai CL, Leung EK. Interferon antibodies may negate the antiviral effects of recombinant alpha-interferon treatment in patients with chronic hepatitis B virus infection. Hepatology. Dec. 1990;12(6):1266-70. Not eligible outcomes. [pmid: 2258142].
282 Lok AS, Lai CL, Wu PC, et al. Alpha-interferon treatment in Chinese patients with chronic hepatitis B. J Hepatol. 1990;11(Suppl 1):S121-5. Secondary data analysis. [pmid: 2079568].
283 Lok AS, Ma OC, Lau JY. Interferon alfa therapy in patients with chronic hepatitis B virus infection. Effects on hepatitis B virus DNA in the liver. Gastroenterology. Mar. 1991;100(3):756-61. Not eligible exposure. [pmid: 1993497].
284 Long Y, Lin XT, Zeng KL, et al. Efficacy of intramuscular matrine in the treatment of chronic hepatitis B. Hepatobiliary Pancreat Dis Int. Feb. 2004;3(1):69-72. Not eligible exposure. [pmid: 14969841].
285 Looney RJ, Hasan MS, Coffin D, et al. Hepatitis B immunization of healthy elderly adults: relationship between naive CD4+ T cells and primary immune response and evaluation of GM-CSF as an adjuvant. J Clin Immunol. Jan. 2001;21(1):30-6. Not eligible target population. [pmid: 11321236].
286 Lu SC, Yan LN, Li B, et al. Lamivudine prophylaxis of liver allograft HBV reinfection in HBV related cirrhotic patients after liver transplantation. Hepatobiliary Pancreat Dis Int. Feb. 2004;3(1):26-32. Not eligible target population. [pmid: 14969833].
287 Main J, Brown JL, Howells C, et al. A double blind, placebo-controlled study to assess the effect of famciclovir on virus replication in patients with chronic hepatitis B virus infection. J Viral Hepat. Jul. 1996;3(4):211-5. Unapproved treatment. [pmid: 8871884].
288 Manesis EK, Giannoulis G, Zoumboulis P, et al. Treatment of hepatocellular carcinoma with combined suppression and inhibition of sex hormones: a randomized, controlled trial. Hepatology. Jun. 1995;21(6):1535-42. Not eligible exposure. [pmid: 7768497].
289 Manesis EK, Hadziyannis ES, Angelopoulou OP, et al. Prediction of treatment-related HBsAg loss in HBeAG-negative chronic hepatitis B: a clue from serum HBsAg levels. Antivir Ther. 2007;12(1):73-82. Not eligible outcomes. [pmid: 17503750].
290 Manolakopoulos S, Bethanis S, Elefsiniotis J, et al. Lamivudine monotherapy in HBeAg-negative chronic hepatitis B: prediction of response-breakthrough and long-term clinical outcome. Aliment Pharmacol Ther. Mar 15. 2006;23(6):787-95. Not eligible outcome. [pmid: 16556181].
291 Manolakopoulos S, Bethanis S, Liapi C, et al. An assessment of serum leptin levels in patients with chronic viral hepatitis: a prospective study. BMC Gastroenterol. 2007;7:17. Not eligible exposure. [pmid: 17540037].
292 Marcellin P, Mommeja-Marin H, Sacks SL, et al. A phase II dose-escalating trial of clevudine in patients with chronic hepatitis B. Hepatology. Jul. 2004;40(1):140-8. Not eligible outcomes. [pmid: 15239097].
293 March JC, Oviedo-Joekes E, Perea-Milla E, et al. Controlled trial of prescribed heroin in the treatment of opioid addiction. J Subst Abuse Treat. Sep. 2006;31(2):203-11. Not eligible target population. [pmid: 16919749].
294 Marchou B, Excler JL, Bourderioux C, et al. A 3-week hepatitis B vaccination schedule provides rapid and persistent protective immunity: a multicenter, randomized trial comparing accelerated and classic vaccination schedules. J Infect Dis. Jul. 1995;172(1):258-60. Not eligible target population. [pmid: 7797926].
295 Marchou B, Picot N, Chavanet P, et al. Three-week hepatitis B vaccination provides protective immunity. Vaccine. Nov. 1993;11(14):1383-5. Not eligible target population. [pmid: 8310757].
296 Margolis HS, Handsfield HH, Jacobs RJ, et al. Evaluation of office-based intervention to improve prevention counseling for patients at risk for sexually acquired hepatitis B virus infection. Hepatitis B-WARE Study Group. Am J Obstet Gynecol. Jan. 2000;182(1 Pt 1):1-6. Not eligible target population. [pmid: 10649147].
297 Marrone A, Zampino R, Portella G, et al. Three-phase sequential combined treatment with lamivudine and interferon in young patients with chronic hepatitis B. J Viral Hepat. Mar. 2005;12(2):186-91. Case-series. [pmid: 15720534].
298 Marsano LS, Greenberg RN, Kirkpatrick RB, et al. Comparison of a rapid hepatitis B immunization schedule to the standard schedule for adults. Am J Gastroenterol. Jan. 1996;91(1):111-5. Not eligible target population. [pmid: 8561109].
299 Marsano LS, West DJ, Chan I, et al. A two-dose hepatitis B vaccine regimen: proof of priming and memory responses in young adults. Vaccine. Apr. 1998;16(6):624-9. Not eligible target population. [pmid: 9569474].
300 Martin J, Bosch O, Moraleda G, et al. Pilot study of recombinant human granulocyte-macrophage colony-stimulating factor in the treatment of chronic hepatitis B. Hepatology. Oct. 1993;18(4):775-80. Unapproved itnervention. [pmid: 8406350].
301 Martin P, Hann HW, Westerberg S, et al. Interferon-alpha2b therapy is efficacious in Asian-Americans with chronic hepatitis B infection: a prospective controlled trial. Dig Dis Sci. Apr. 1998;43(4):875-9. Case-series. [pmid: 9580255].
302 Matamoros N, De Gracia J, Hernandez F, et al. A prospective controlled crossover trial of a new presentation (10% vs. 5%) of a heat-treated intravenous immunoglobulin. Int Immunopharmacol. Mar. 2005;5(3):619-26. Not eligible exposure. [pmid: 15683857].
303 Mathei C, Van Damme P, Meheus A. Hepatitis B vaccine administration: comparison between jet-gun and syringe and needle. Vaccine. Mar. 1997;15(4):402-4. Not eligible target population. [pmid: 9141211].
304 Maxwell PR, Flisiak R. Evaluation of alpha-glutathione-S-transferase as a biomarker of lamivudine therapy for chronic hepatitis B. Dig Dis Sci. Oct. 2006;51(10):1706-11. Case-series. [pmid: 16983502].
305 Mazzaferro V, Romito R, Schiavo M, et al. Prevention of hepatocellular carcinoma recurrence with alpha-interferon after liver resection in HCV cirrhosis. Hepatology. Dec. 2006;44(6):1543-54. Not eligible target population. [pmid: 17133492].
306 Mazzella G, Accogli E, Sottili S, et al. Alpha interferon treatment may prevent hepatocellular carcinoma in HCV-related liver cirrhosis. J Hepatol. Feb. 1996;24(2):141-7. Not eligible target population. [pmid: 8907566].
307 Mazzella G, Saracco G, Festi D, et al. Long-term results with interferon therapy in chronic type B hepatitis: a prospective randomized trial. Am J Gastroenterol. Aug. 1999;94(8):2246-50. Unapproved itnervention. [pmid: 10445557].
308 McDermott AB, Cohen SB, Zuckerman JN, et al. Human leukocyte antigens influence the immune response to a pre-S/S hepatitis B vaccine. Vaccine. Jan 28. 1999;17(4):330-9. Not eligible target population. [pmid: 9987171].
309 McKenzie R, Fried MW, Sallie R, et al. Hepatic failure and lactic acidosis due to fialuridine (FIAU), an investigational nucleoside analogue for chronic hepatitis B. N Engl J Med. Oct 26. 1995;333(17):1099-105. Unapproved itnervention. [pmid: 7565947].
310 Meydani SN, Meydani M, Blumberg JB, et al. Vitamin E supplementation and in vivo immune response in healthy elderly subjects. A randomized controlled trial. JAMA. May 7. 1997;277(17):1380-6. Not eligible target population. [pmid: 9134944].
311 Mihm U, Gartner BC, Faust D, et al. Viral kinetics in patients with lamivudine-resistant hepatitis B during adefovir-lamivudine combination therapy. J Hepatol. Aug. 2005;43(2):217-24. Case-series. [pmid: 15964093].
312 Milne A, Hopkirk N, Lucas CR, et al. Failure of New Zealand hepatitis B carriers to respond to Phyllanthus amarus. N Z Med J. Jun 22. 1994;107(980):243. Not eligible exposure. [pmid: 8208497].
313 Milne AA, Murphy WG, Reading SJ, et al. A randomised trial of fibrin sealant in peripheral vascular surgery. Vox Sang. 1996;70(4):210-2. Not eligible exposure. [pmid: 9123925].
314 Minelli R, Braverman LE, Valli MA, et al. Recombinant interferon alpha (rIFN-alpha) does not potentiate the effect of iodine excess on the development of thyroid abnormalities in patients with HCV chronic active hepatitis. Clin Endocrinol (Oxf). Jan. 1999;50(1):95-100. Not eligible target population. [pmid: 10341861].
315 Miskovsky E, Gershman K, Clements ML, et al. Comparative safety and immunogenicity of yeast recombinant hepatitis B vaccines containing S and pre-S2 + S antigens. Vaccine. May. 1991;9(5):346-50. Not eligible target population. [pmid: 1872019].
316 Mitchell JR, Whitney FW. The effect of injection speed on the perception of intramuscular injection pain. A clinical update. AAOHN J. Jun. 2001;49(6):286-92. Not eligible target population. [pmid: 11760527].
317 Moe SM, Zekonis M, Harezlak J, et al. A placebo-controlled trial to evaluate immunomodulatory effects of paricalcitol. Am J Kidney Dis. Oct. 2001;38(4):792-802. Not eligible target population. [pmid: 11576883].
318 Morimitsu Y, Kleiner DE Jr, Conjeevaram HS, et al. Expression of transforming growth factor alpha in the liver before and after interferon alfa therapy for chronic hepatitis B. Hepatology. Oct. 1995;22(4 Pt 1):1021-6. Not eligible outcomes. [pmid: 7557846].
319 Moschos M, Manesis E, Panagakis E, et al. The effect of low-dose interferon treatment on visual evoked potentials. Doc Ophthalmol. 1997;94(3):215-21. Not eligible outcomes. [pmid: 9682991].
320 Mould GP, Sutton JA, Matejtschuk P, et al. Solvent/detergent treatment does not alter the tolerance or uptake of human normal immunoglobulin for intramuscular injection. Vox Sang. Apr. 2001;80(3):151-8. Not eligible target population. [pmid: 11449954].
321 Murray KD, El-Mohandes AA, El-Khorazaty MN, et al. Low-income minority mothers' reports of infant health care utilisation compared with medical records. Paediatr Perinat Epidemiol. May. 2007;21(3):274-83. Not eligible target population. [pmid: 17439537].
322 Musch E, Malek M, von Eick H, et al. Successful application of highly purified natural interferon alpha (multiferon) in a chronic hepatitis C patient resistant to preceding treatment approaches. Hepatogastroenterology. Sep–Oct. 2004;51(59):1476-9. Case Reports. [pmid: 15362781].
323 Mutchnick MG, Appelman HD, Chung HT, et al. Thymosin treatment of chronic hepatitis B: a placebo-controlled pilot trial. Hepatology. Sep. 1991;14(3):409-15. Unapproved itnervention. [pmid: 1874487].
324 Mutchnick MG, Lindsay KL, Schiff ER, et al. Thymosin alpha1 treatment of chronic hepatitis B: results of a phase III multicentre, randomized, double-blind and placebo-controlled study. J Viral Hepat. Sep. 1999;6(5):397-403. Unapproved itnervention. [pmid: 10607256].
325 Nagaraju K, Misra S, Saraswat S, et al. High prevalence of HBV infectivity in blood donors detected by the dot blot hybridisation assay. Vox Sang. 1994;67(2):183-6. Not eligible target population.
326 Nam SW, Jung JJ, Bae SH, et al. Clinical outcomes of delayed clearance of serum HBsAG in patients with chronic HBV infection. Korean J Intern Med. Jun. 2007;22(2):73-6. Not eligible outcomes. [pmid: 17616021].
327 Naoumov NV, Lopes AR, Burra P, et al. Randomized trial of lamivudine versus hepatitis B immunoglobulin for long-term prophylaxis of hepatitis B recurrence after liver transplantation. J Hepatol. Jun. 2001;34(6):888-94. Not eligible target population. [pmid: 11451173].
328 Nardelli-Haefliger D, Kraehenbuhl JP, Curtiss R 3rd, et al. Oral and rectal immunization of adult female volunteers with a recombinant attenuated Salmonella typhi vaccine strain. Infect Immun. Dec. 1996;64(12):5219-24. Not eligible target population. [pmid: 8945569].
329 Narendranathan M, Remla A, Mini PC, et al. A trial of Phyllanthus amarus in acute viral hepatitis. Trop Gastroenterol. Oct–Dec. 1999;20(4):164-6. Not eligible target population. [pmid: 10769603].
330 Natsuizaka M, Hige S, Ono Y, et al. Long-term follow-up of chronic hepatitis B after the emergence of mutations in the hepatitis B virus polymerase region. J Viral Hepat. Mar. 2005;12(2):154-9. Case-series. [pmid: 15720530].
331 Nevens F, Zuckerman JN, Burroughs AK, et al. Immunogenicity and safety of an experimental adjuvanted hepatitis B candidate vaccine in liver transplant patients. Liver Transpl. Oct. 2006;12(10):1489-95. Not eligible target population. [pmid: 16964595].
332 Nguyen BH, Nguyen KP, McPhee SJ, et al. Promoting cancer prevention activities among Vietnamese physicians in California. J Cancer Educ. Summer. 2000;15(2):82-5. Not eligible target population. [pmid: 10879896].
333 Nicoletti R, Porro CA, Brighetti G, et al. Long-term effects of vaccination on attentional performance. Vaccine. Sep 28. 2004;22(2930):3877-81. Not eligible target population. [pmid: 15364434].
334 Niederau C, Strohmeyer G, Heintges T, et al. Polyunsaturated phosphatidyl-choline and interferon alpha for treatment of chronic hepatitis B and C: a multi-center, randomized, double-blind, placebo-controlled trial. Leich Study Group Hepatogastroenterology. May–Jun. 1998;45(21):797-804. Unapproved itnervention.
335 Niro GA, Ciancio A, Gaeta GB, et al. Pegylated interferon alpha-2b as monotherapy or in combination with ribavirin in chronic hepatitis delta. Hepatology. Sep. 2006;44(3):713-20. Not eligible target population. [pmid: 16941685].
336 Niro GA, Ciancio A, Tillman HL, et al. Lamivudine therapy in chronic delta hepatitis: a multicentre randomized-controlled pilot study. Aliment Pharmacol Ther. Aug 1. 2005;22(3):227-32. Not eligible target population. [pmid: 16091060].
337 Nothdurft HD, Dietrich M, Zuckerman JN, et al. Rapid protection against hepatitis A and B using an accelerated vaccination schedule: comparison of combined vaccine, Twinrix, with separate vaccines. BioDrugs. 2003;17(Suppl 1):15-8. Not eligible target population. [pmid: 12785873].
338 Nothdurft HD, Dietrich M, Zuckerman JN, et al. A new accelerated vaccination schedule for rapid protection against hepatitis A and B. Vaccine. Jan 15. 2002;20(78):1157-62. Not eligible target population. [pmid: 11803077].
339 Nuchprayoon C, RO OC, Vaivanijkul J, et al. Studies of immune response to hepatitis B vaccine in Thai blood donors. Southeast Asian J Trop Med Public Health. Mar. 1992;23(1):17-21. Not eligible target population.
340 Nunez M, Ramos B, Diaz-Pollan B, et al. Virological outcome of chronic hepatitis B virus infection in HIV-coinfected patients receiving anti-HBV active antiretroviral therapy. AIDS Res Hum Retroviruses. Sep. 2006;22(9):842-8. Case-series. [pmid: 16989608].
341 Oguz Y, Doganci L, Vural A. Seroconversion rates of two different doses of hepatitis B vaccine in Turkish haemodialysis patients. Cent Eur J Public Health. Feb. 2001;9(1):44-5. Not eligible target population. [pmid: 11243591].
342 Oka H, Yamamoto S, Kuroki T, et al. Prospective study of chemoprevention of hepatocellular carcinoma with Sho-saiko-to (TJ-9). Cancer. Sep 1. 1995;76(5):743-9. Not eligible exposure. [pmid: 8625175].
343 Ola SO, Anomneze EE, Chukwuani CM, et al. Interferon alfa-2a (Roferon-A) in the management of chronic hepatitis B infection: results of an open prospective study in Nigerian patients. West Afr J Med. Oct–Dec. 2000;19(4):259-64. Case-series. [pmid: 11391836].
344 Oliveira GA, Wetzel K, Calvo-Calle JM, et al. Safety and enhanced immunogenicity of a hepatitis B core particle Plasmodium falciparum malaria vaccine formulated in adjuvant Montanide ISA 720 in a phase I trial. Infect Immun. Jun. 2005;73(6):3587-97. Not eligible target population. [pmid: 15908388].
345 Oliveira PM, Silva AE, Kemp VL, et al. Comparison of three different schedules of vaccination against hepatitis B in health care workers. Vaccine. Jun. 1995;13(9):791-4. Not eligible target population. [pmid: 7483798].
346 Oliveri F, Santantonio T, Bellati G, et al. Long term response to therapy of chronic anti-HBe-positive hepatitis B is poor independent of type and schedule of interferon. Am J Gastroenterol. May. 1999;94(5):1366-72. Unapproved itnervention. [pmid: 10235220].
347 Otag F. False positive HBsAg result in blood donors due to administration of three different recombinant DNA Hepatitis B vaccines. Vaccine. Sep 8. 2003;21(2526):3734-7. Not eligible target population. [pmid: 12922105].
348 Ozener C, Fak AS, Avsar E, et al. The effect of alpha interferon therapy and short-interval intradermal administration on response to hepatitis B vaccine in haemodialysis patients. Nephrol Dial Transplant. May. 1999;14(5):1339-40. Not eligible target population. [pmid: 10344404].
349 Parish DC, Muecke HW, Joiner TA, et al. Immunogenicity of low-dose intradermal recombinant DNA hepatitis B vaccine. South Med J. Apr. 1991;84(4):426-30. Not eligible target population. [pmid: 1826567].
350 Park NH, Shin JW, Park JH, et al. Monitoring of HBeAg levels may help to predict the outcomes of lamivudine therapy for HBeAg positive chronic hepatitis B. J Viral Hepat. Mar. 2005;12(2):216-21. No associative hypothesis tested. [pmid: 15720539].
351 Park SJ, Paik SW, Choi MS, et al. Is lamivudine with 1-week HBlg as effective as long-term high-dose HBlg in HBV prophylaxis after liver transplantation?. Transplant Proc. Jun. 2002;34(4):1252-4. Not eligible target population. [pmid: 12072331].
352 Pastore G, Santantonio T, Milella M, et al. Anti-HBe-positive chronic hepatitis B with HBV-DNA in the serum response to a 6-month course of lymphoblastoid interferon. J Hepatol. Mar. 1992;14(23):221-5. Unapproved itnervention. [pmid: 1500686].
353 Peng YC, Chan CS, Chen GH. The effectiveness of serum alpha-fetoprotein level in anti-HCV positive patients for screening hepatocellular carcinoma. Hepatogastroenterology. Nov–Dec. 1999;46(30):3208-11. Not eligible target population. [pmid: 10626187].
354 Pennie RA, O'Connor AM, Dulberg CS, et al. Low-cost hepatitis B vaccine improves uptake among self-paying health-care students. J Med Virol. May. 1992;37(1):48-53. Not eligible target population. [pmid: 1535653].
355 Perez-Garcia R, Perez-Garcia A, Verbeelen D, et al. AM3 (Inmunoferon) as an adjuvant to hepatitis B vaccination in hemodialysis patients. Kidney Int. May. 2002;61(5):1845-52. Not eligible target population. [pmid: 11967036].
356 Peters MG, Andersen J, Lynch P, et al. Randomized controlled study of tenofovir and adefovir in chronic hepatitis B virus and HIV infection: ACTG A5127. Hepatology. Nov. 2006;44(5):1110-6. Not eligible exposure, pending FDA approval, spring 2008. [pmid: 17058225].
357 Petrie KJ, Booth RJ, Pennebaker JW, et al. Disclosure of trauma and immune response to a hepatitis B vaccination program. J Consult Clin Psychol. Oct. 1995;63(5):787-92. Not eligible target population. [pmid: 7593871].
358 Piao CY, Fujioka S, Iwasaki Y, et al. Lamivudine treatment in patients with HBV-related hepatocellular carcinoma—using an untreated, matched control cohort. Acta Med Okayama. Oct. 2005;59(5):217-24. Not eligible target population. [pmid: 16286955].
359 Pol S, Couillin I, Michel ML, et al. Immunotherapy of chronic hepatitis B by anti HBV vaccine. Acta Gastroenterol Belg. Apr–Jun. 1998;61(2):228-33. Unapproved itnervention. [pmid: 9658616].
360 Pozzi M, Grassi G, Ratti L, et al. Cardiac, neuroadrenergic, and portal hemodynamic effects of prolonged aldosterone blockade in postviral child A cirrhosis. Am J Gastroenterol. May. 2005;100(5):1110-6. Not eligible target population. [pmid: 15842586].
361 Prado V, Riedemann S, Ibarra H, et al. Immunogenicity and reactogenicity of a combined hepatitis A and B vaccine in healthy Chilean subjects. Int J Infect Dis. Jun. 2002;6(2):129-33. Not eligible target population. [pmid: 12121601].
362 Pramoolsinsap C, Sirikulchayanonta V, Busakorn W, et al. Coinfections with hepatitis g and/or c virus in hepatitis B-related chronic liver disease. Southeast Asian J Trop Med Public Health. Dec. 1999;30(4):741-9. Not eligible outcomes. [pmid: 10928369].
363 Proell S. Immunisation against hepatitis A, hepatitis B and typhoid fever via combined vaccination: rationale, immunogenicity and reactogenicity. BioDrugs. 2003;17(Suppl 1):7-10. Not eligible target population. [pmid: 12785871].
364 Proell S, Maiwald H, Nothdurft HD, et al. Combined vaccination against hepatitis A, hepatitis B, and typhoid fever: safety, reactogenicity, and immunogenicity. J Travel Med. May–Jun. 2002;9(3):122-6. Not eligible target population. [pmid: 12088576].
365 Propst T, Propst A, Lhotta K, et al. Reinforced intradermal hepatitis B vaccination in hemodialysis patients is superior in antibody response to intramuscular or subcutaneous vaccination. Am J Kidney Dis. Dec. 1998;32(6):1041-5. Not eligible target population. [pmid: 9856522].
366 Quiroga JA, Castillo I, Porres JC, et al. Recombinant gamma-interferon as adjuvant to hepatitis B vaccine in hemodialysis patients. Hepatology. Oct. 1990;12(4 Pt 1):661-3. Not eligible target population. [pmid: 2145212].
367 Radecke K, Protzer U, Trippler M, et al. Selection of hepatitis B virus variants with aminoacid substitutions inside the core antigen during interferon-alpha therapy. J Med Virol. Dec. 2000;62(4):479-86. Case-series. [pmid: 11074477].
368 Rakela J, Wood JR, Czaja AJ, et al. Long-term versus short-term treatment with recombinant interferon alfa-2a in patients with chronic hepatitis B: a prospective, randomized treatment trial. Mayo Clin Proc. Oct. 1990;65(10):1330-5. Unapproved itnervention. [pmid: 2214880].
369 Ramon JM, Bou R, Oromi J. Low-dose intramuscular revaccination against hepatitis B. Vaccine. Dec. 1996;14(1718):1647-50. Not eligible target population. [pmid: 9032894].
370 Ramonet M, da Silveira TR, Lisker-Melman M, et al. A two-dose combined vaccine against hepatitis A and hepatitis B in healthy children and adolescents compared to the corresponding monovalent vaccines. Arch Med Res. Jan–Feb. 2002;33(1):67-73. Not eligible target population. [pmid: 11825634].
371 Rapti I, Dimou E, Mitsoula P, et al. Adding-on versus switching-to adefovir therapy in lamivudine-resistant HBeAg-negative chronic hepatitis B. Hepatology. Feb. 2007;45(2):307-13. Small sample size. [pmid: 17256746].
372 Raz R, Koren R, Bass D. Safety and immunogenicity of a new mammalian cell-derived recombinant hepatitis B vaccine containing Pre-S1 and Pre-S2 antigens in adults. Isr Med Assoc J. May. 2001;3(5):328-32. Not eligible target population. [pmid: 11411195].
373 Realdi G, Diodati G, Bonetti P, et al. Recombinant human interferon alfa-2a in community-acquired non-A, non-B chronic active hepatitis. Preliminary results of a randomized, controlled trial. J Hepatol. 1990;11(Suppl 1):S68-71. Not eligible target population. [pmid: 2127791].
374 Realdi G, Fattovich G, Pastore G, et al. Problems in the management of chronic hepatitis B with interferon: experience in a randomized, multicentre study. J Hepatol. 1990;11(Suppl 1):S129-32. Unapproved itnervention. [pmid: 2079570].
375 Rebedea I, Diaconescu IG, Bach D, et al. Comparison of thiomersal-free and thiomersal-containing formulations of a recombinant hepatitis B vaccine (Hepavax-Gene) in healthy adults. Vaccine. Jun 19. 2006;24(25):5320-6. Not eligible target population. [pmid: 16707195].
376 Ren A, Feng F, Ma J, et al. Immunogenicity and safety of a new inactivated hepatitis A vaccine in young adults: a comparative study. Chin Med J (Engl). Oct. 2002;115(10):1483-5. Not eligible target population. [pmid: 12490092].
377 Rendi-Wagner P, Shouval D, Genton B, et al. Comparative immunogenicity of a PreS/S hepatitis B vaccine in non- and low responders to conventional vaccine. Vaccine. Apr 5. 2006;24(15):2781-9. Not eligible target population. [pmid: 16455169].
378 Rieger MA, Hofmann F, Michaelis M. Simultaneous vaccination against hepatitis A and B: results of an open, randomized study from the occupational health point of view. Int J Occup Med Environ Health. 2004;17(3):379-91. Not eligible target population. [pmid: 15683159].
379 Rigopoulou EI, Suri D, Chokshi S, et al. Lamivudine plus interleukin-12 combination therapy in chronic hepatitis B: antiviral and immunological activity. Hepatology. Nov. 2005;42(5):1028-36. Unapproved itnervention. [pmid: 16250037].
380 Ristola MA, Vuola JM, Valle M, et al. Antibody responses to intradermal recombinant hepatitis B immunization among HIV-positive subjects. Vaccine. Nov 25. 2004;23(2):205-9. Not eligible target population. [pmid: 15531038].
381 Rizzetto M, Volpes R, Smedile A. Response of pre-core mutant chronic hepatitis B infection to lamivudine. J Med Virol. Jul. 2000;61(3):398-402. Secondary data analysis. [pmid: 10861653].
382 Roberts LK, Barr LJ, Fuller DH, et al. Clinical safety and efficacy of a powdered Hepatitis B nucleic acid vaccine delivered to the epidermis by a commercial prototype device. Vaccine. Sep 23. 2005;23(40):4867-78. Not eligible target population. [pmid: 15985318].
383 Roche B, Feray C, Gigou M, et al. HBV DNA persistence 10 years after liver transplantation despite successful anti-HBS passive immunoprophylaxis. Hepatology. Jul. 2003;38(1):86-95. Not eligible target population. [pmid: 12829990].
384 Rodriguez-Inigo E, Bartolome J, Lopez-Alcorocho JM, et al. Activation of liver disease in healthy hepatitis B surface antigen carriers during interferon-alpha treatment. J Med Virol. Sep. 1997;53(1):76-80. Not eligible target population. [pmid: 9298736].
385 Roozbeh J, Moini M, Lankarani KB, et al. Low dose intradermal versus high dose intramuscular hepatitis B vaccination in patients on chronic hemodialysis. ASAIO J. May–Jun. 2005;51(3):242-5. Not eligible target population. [pmid: 15968954].
386 Rose RM, Rey-Martinez J, Croteau C, et al. Failure of recombinant interleukin-2 to augment the primary humoral response to a recombinant hepatitis B vaccine in healthy adults. J Infect Dis. Apr. 1992;165(4):775-7. Not eligible target population.
387 Rosina F, Pintus C, Meschievitz C, et al. Long term interferon treatment of chronic delta hepatitis: a multicenter Italian study. Prog Clin Biol Res. 1991;364:385-91. Not eligible target population. [pmid: 2020713].
388 Rosman AS, Basu P, Galvin K, et al. Efficacy of a high and accelerated dose of hepatitis B vaccine in alcoholic patients: a randomized clinical trial. Am J Med. Sep. 1997;103(3):217-22. Not eligible target population. [pmid: 9316554].
389 Rost KL, Wierich W, Masayuki F, et al. Pharmacokinetics of thymosin alpha1 after subcutaneous injection of three different formulations in healthy volunteers. Int J Clin Pharmacol Ther. Jan. 1999;37(1):51-7. Not eligible target population. [pmid: 10027483].
390 Roux CH, Brocq O, Breuil V, et al. Safety of anti-TNF-alpha therapy in rheumatoid arthritis and spondylarthropathies with concurrent B or C chronic hepatitis. Rheumatology (Oxford). Oct. 2006;45(10):1294-7. Case Reports. [pmid: 16603583].
391 Rumi M, Romeo R, De Filippi F, et al. A multicentre randomized clinical trial of recombinant alpha-2a interferon therapy in patients with chronic hepatitis B. Ital J Gastroenterol. Apr. 1993;25(3):117-20. Unapproved treatment. [pmid: 8507888].
392 Rustgi VK, Schleupner CJ, Krause DS. Comparative study of the immunogenicity and safety of Engerix-B administered at 0, 1, 2 and 12 months and Recombivax HB administered at 0, 1, and 6 months in healthy adults. Vaccine. Dec. 1995;13(17):1665-8. Not eligible target population. [pmid: 8719517].
393 Safadi R, Israeli E, Papo O, et al. Treatment of chronic hepatitis B virus infection via oral immune regulation toward hepatitis B virus proteins. Am J Gastroenterol. Nov. 2003;98(11):2505-15. Case-series. [pmid: 14638356].
394 Saitta C, Pontisso P, Brunetto MR, et al. Virological profiles in hepatitis B virus/hepatitis C virus coinfected patients under interferon plus ribavirin therapy. Antivir Ther. 2006;11(7):931-4. Case-series. [pmid: 17302256].
395 Sakai T, Shiraki K, Inoue H, et al. Efficacy of long-term interferon therapy in chronic hepatitis B patients with HBV genotype C. Int J Mol Med. Aug. 2002;10(2):201-4. Case-series. [pmid: 12119559].
396 Sangfelt P, Uhnoo I, Hollander A, et al. Lamivudine and famciclovir combination therapy with or without addition of interferon-alpha-2b for HBeAg-positive chronic hepatitis B: a pilot study. Scand J Infect Dis. 2002;34(7):505-11. Unapproved itnervention. [pmid: 12195876].
397 Sansom S, Rudy E, Strine T, et al. Hepatitis A and B vaccination in a sexually transmitted disease clinic for men who have sex with men. Sex Transm Dis. Sep. 2003;30(9):685-8. Not eligible target population. [pmid: 12972790].
398 Santantonio T, Niro GA, Sinisi E, et al. Lamivudine/interferon combination therapy in anti-HBe positive chronic hepatitis B patients: a controlled pilot study. J Hepatol. Jun. 2002;36(6):799-804. Unapproved itnervention. [pmid: 12044531].
399 Sarin SK, Sandhu BS, Sharma BC, et al. Beneficial effects of ‘lamivudine pulse’ therapy in HBeAg-positive patients with normal ALT*. J Viral Hepat. Nov. 2004;11(6):552-8. Case-series. [pmid: 15500556].
400 Saruc M, Ozden N, Turkel N, et al. Long-term outcomes of thymosin-alpha 1 and interferon alpha-2b combination therapy in patients with hepatitis B e antigen (HBeAg) negative chronic hepatitis B. J Pharm Sci. Jul. 2003;92(7):1386-95. Not eligible exposure. [pmid: 12820143].
401 Sasaki MG, Foccacia R, de Messias-Reason IJ. Efficacy of granulocyte-macrophage colony-stimulating factor (GM-CSF) as a vaccine adjuvant for hepatitis B virus in patients with HIV infection. Vaccine. Nov 7. 2003;21(31):4545-9. Not eligible target population. [pmid: 14575766].
402 Schiff GM, Sherwood JR, Zeldis JB, et al. Comparative study of the immunogenicity and safety of two doses of recombinant hepatitis B vaccine in healthy adolescents. J Adolesc Health. Jan. 1995;16(1):12-7. Not eligible target population. [pmid: 7742331].
403 Schiffl H, Wendinger H, Lang SM. Ultrapure dialysis fluid and response to hepatitis B vaccine. Nephron. Jul. 2002;91(3):530-1. Not eligible target population. [pmid: 12119493].
404 Scully LJ, Brown D, Lloyd C, et al. Immunological studies before and during interferon therapy in chronic HBV infection: identification of factors predicting response. Hepatology. Nov. 1990;12(5):1111-7. Unapproved itnervention. [pmid: 1699861].
405 Seal KH, Kral AH, Lorvick J, et al. A randomized controlled trial of monetary incentives vs. outreach to enhance adherence to the hepatitis B vaccine series among injection drug users. Drug Alcohol Depend. Aug 20. 2003;71(2):127-31. Not eligible target population. [pmid: 12927650].
406 Sellors J, Pickard L, Mahony JB, et al. Understanding and enhancing compliance with the second dose of hepatitis B vaccine: a cohort analysis and a randomized controlled trial. CMAJ. Jul 15. 1997;157(2):143-8. Not eligible target population. [pmid: 9238142].
407 Senturk H, Tabak F, Akdogan M, et al. Therapeutic vaccination in chronic hepatitis B. J Gastroenterol Hepatol. Jan. 2002;17(1):72-6. Unapproved itnervention. [pmid: 11895556].
408 Seremetis SV, Aledort LM, Bergman GE, et al. Three-year randomised study of high-purity or intermediate-purity factor VIII concentrates in symptom-free HIV-seropositive haemophiliacs: effects on immune status. Lancet. Sep 18. 1993;342(8873):700-3. Not eligible target population. [pmid: 8103820].
409 Shapira MY, Zeira E, Adler R, et al. Rapid seroprotection against hepatitis B following the first dose of a Pre-S1/Pre-S2/S vaccine. J Hepatol. Jan. 2001;34(1):123-7. Not eligible target population. [pmid: 11211888].
410 Sharif F, Mohebbi S, Tabatabaee HR, et al. Effects of psycho-educational intervention on health-related quality of life (QOL) of patients with chronic liver disease referring to Shiraz University of Medical Sciences. Health Qual Life Outcomes. 2005;3:81. Not eligible exposure. [pmid: 16356186].
411 Shen WS, Yang HZ, Hong Q, et al. Two-year observation of the clinical efficacy in treating chronic hepatitis B Patients with Ganxian recipe and lamivudine. Chin J Integr Med. Mar. 2005;11(1):5-10. Not eligible exposure. [pmid: 15975299].
412 Sherman M, Peltekian KM, Lee C. Screening for hepatocellular carcinoma in chronic carriers of hepatitis B virus: incidence and prevalence of hepatocellular carcinoma in a North American urban population. Hepatology. Aug. 1995;22(2):432-8. Not eligible exposure. [pmid: 7543434].
413 Shi J, Hao JH, Ren WH, et al. Effects of heparin on liver fibrosis in patients with chronic hepatitis B. World J Gastroenterol. Jul. 2003;9(7):1611-4. Not eligible outcomes. [pmid: 12854176].
414 Shin JW, Chung YH, Choi MH, et al. Precore stop codon mutation of hepatitis B virus is associated with low breakthrough rate following long-term lamivudine therapy. J Gastroenterol Hepatol. Jun. 2005;20(6):844-9. Not eligible outcomes. [pmid: 15946130].
415 Shin JW, Park NH, Jung SW, et al. Clinical significance of hepatitis B e antigen level measurement during long-term lamivudine therapy in chronic hepatitis B patients with e antigen positive. World J Gastroenterol. Nov 7. 2006;12(41):6693-8. Not eligible outcomes. [pmid: 17075986].
416 Shiomi S, Nishiguchi S, Kubo S, et al. Vitamin K2 (menatetrenone) for bone loss in patients with cirrhosis of the liver. Am J Gastroenterol. Apr. 2002;97(4):978-81. Not eligible target population. [pmid: 12003435].
417 Singh NP, Mandal SK, Thakur A, et al. Efficacy of GM-CSF as an adjuvant to hepatitis B vaccination in patients with chronic renal failure—results of a prospective, randomized trial. Ren Fail. Mar. 2003;25(2):255-66. Not eligible target population. [pmid: 12739832].
418 Sipe JC, Romine JS, Koziol JA, et al. Cladribine in treatment of chronic progressive multiple sclerosis. Lancet. Jul 2. 1994;344(8914):9-13. Not eligible target population. [pmid: 7912347].
419 Smit-Leijs MB, Kramer P, Heijtink RA, et al. Hepatitis B vaccination of haemodialysis patients: randomized controlled trial comparing plasma-derived vaccine with and without pre-S2 antigen. Eur J Clin Invest. Oct. 1990;20(5):540-5. Not eligible target population. [pmid: 2124986].
420 Somboonsilp W, Eiam-Ong S, Tungsanga K, et al. Immune response of intradermal hepatitis B vaccination at lower dose versus intramuscular vaccination at double standard dose in predialytic chronic renal failure patients. J Med Assoc Thai. Dec. 2003;86(12):1122-7. Not eligible target population. [pmid: 14971519].
421 Somjee S, Pai S, Parikh P, et al. Passive active prophylaxis against Hepatitis B in children with acute lymphoblastic leukemia. Leuk Res. Nov. 2002;26(11):989-92. Not eligible target population. [pmid: 12363466].
422 Soon DK, Lowe SL, Teng CH, et al. Safety and efficacy of alamifovir in patients with chronic hepatitis B virus infection. J Hepatol. Nov. 2004;41(5):852-8. Unapproved itnervention. [pmid: 15519660].
423 Soyletir G, Bahceci E, Akoglu E, et al. Clinical evaluation of low dose intradermally administered hepatitis B vaccine: a comparison of plasma-derived and recombinant yeast-derived vaccines. Vaccine. 1992;10(5):301-4. Not eligible target population. [pmid: 1533478].
424 Storek J, Dawson MA, Lim LC, et al. Efficacy of donor vaccination before hematopoietic cell transplantation and recipient vaccination both before and early after transplantation. Bone Marrow Transplant. Feb. 2004;33(3):337-46. Not eligible target population. [pmid: 14647254].
425 Sun HC, Tang ZY, Wang L, et al. Postoperative interferon alpha treatment postponed recurrence and improved overall survival in patients after curative resection of HBV-related hepatocellular carcinoma: a randomized clinical trial. J Cancer Res Clin Oncol. Jul. 2006;132(7):458-65. Not eligible target population. [pmid: 16557381].
426 Sung JJ, Wong ML, Bowden S, et al. Intrahepatic hepatitis B virus covalently closed circular DNA can be a predictor of sustained response to therapy. Gastroenterology. Jun. 2005;128(7):1890-7. Not eligible exposure. [pmid: 15940624].
427 Suzuki F, Arase Y, Akuta N, et al. Efficacy of 6-month interferon therapy in chronic hepatitis B virus infection in Japan. J Gastroenterol. Oct. 2004;39(10):969-74. Case-series. [pmid: 15549450].
428 Suzuki H, Iino S, Shiraki K, et al. Safety and efficacy of a recombinant yeast-derived pre-S2 + S-containing hepatitis B vaccine (TGP-943): phase 1, 2 and 3 clinical testing. Vaccine. Sep. 1994;12(12):1090-6. Not eligible target population. [pmid: 7998418].
429 Suzuki T, Yamauchi K, Kuwata T, et al. Characterization of hepatitis B virus surface antigen-specific CD4+ T cells in hepatitis B vaccine non-responders. J Gastroenterol Hepatol. Aug. 2001;16(8):898-903. Not eligible target population. [pmid: 11555104].
430 Tacket CO, Losonsky G, Lubeck MD, et al. Initial safety and immunogenicity studies of an oral recombinant adenohepatitis B vaccine. Vaccine. 1992;10(10):673-6. Not eligible target population. [pmid: 1523878].
431 Tan KT, Rajan DK, Kachura JR, et al. Pain after percutaneous liver biopsy for diffuse hepatic disease: a randomized trial comparing subcostal and intercostal approaches. J Vasc Interv Radiol. Sep. 2005;16(9):1215-9. Not eligible exposure. [pmid: 16151062].
432 Tarhan MO, Aker AI, Sipahi OR, et al. Accelerated versus classical hepatitis B virus vaccination programs in healthcare workers accelerated vs. classical HBV vaccination. Med Sci Monit. Nov. 2006;12(11):CR467-70. Not eligible target population. [pmid: 17072271].
433 Tarr PE, Lin R, Mueller EA, et al. Evaluation of tolerability and antibody response after recombinant human granulocyte-macrophage colony-stimulating factor (rhGM-CSF) and a single dose of recombinant hepatitis B vaccine. Vaccine. Sep. 1996;14(13):1199-204. Not eligible target population. [pmid: 8961505].
434 Tassopoulos NC, Koutelou MG, Polychronaki H, et al. Recombinant interferon-alpha therapy for acute hepatitis B: a randomized, double-blind, placebo-controlled trial. J Viral Hepat. 1997;4(6):387-94. Not eligible target population. [pmid: 9430359].
435 Taylor JA, Davis RL, Kemper KJ. Health care utilization and health status in high-risk children randomized to receive group or individual well child care. Pediatrics. Sep. 1997;100(3):E1. Not eligible target population.
436 Taylor VM, Jackson JC, Chan N, et al. Hepatitis B knowledge and practices among Cambodian American women in Seattle, Washington. J Community Health. Jun. 2002;27(3):151-63. Not eligible target population. [pmid: 12027266].
437 Techapaitoon S. Efficacy of high dose interferon—alpha treatment of chronic hepatitis B. J Med Assoc Thai. Nov. 1999;82(11):1118-26. Case-series. [pmid: 10659547].
438 Teran JC, Mullen KD, Hoofnagle JH, et al. Decrease in serum levels of markers of hepatic connective tissue turnover during and after treatment of chronic hepatitis B with interferon-alpha. Hepatology. Apr. 1994;19(4):849-56. Not eligible outcomes. [pmid: 8138256].
439 Thakur V, Guptan RC, Basir SF, et al. Enhanced immunogenicity of recombinant hepatitis B vaccine in exposed family contacts of chronic liver disease patients. Scand J Infect Dis. 2001;33(8):618-21. Not eligible target population. [pmid: 11525358].
440 Thakur V, Sarin SK, Rehman S, et al. Role of HBV genotype in predicting response to lamivudine therapy in patients with chronic hepatitis B. Indian J Gastroenterol. Jan–Feb. 2005;24(1):12-5. Not eligible outcomes. [pmid: 15778519].
441 Thamlikitkul V, Wasuwat S, Kanchanapee P. Efficacy of Phyllanthus amarus for eradication of hepatitis B virus in chronic carriers. J Med Assoc Thai. Sep. 1991;74(9):381-5. Not eligible exposure. [pmid: 1791391].
442 Thoelen S, Van Damme P, Mathei C, et al. Safety and immunogenicity of a hepatitis B vaccine formulated with a novel adjuvant system. Vaccine. Apr. 1998;16(7):708-14. Not eligible target population. [pmid: 9562690].
443 Thomas HC, Karayiannis P, Brook G. Treatment of hepatitis B virus infection with interferon. Factors predicting response to interferon. J Hepatol. 1991;13(Suppl 1):S4-7. Unapproved itnervention. [pmid: 1960378].
444 Thomas HC, Lok AS, Carreno V, et al. Comparative study of three doses of interferon-alpha 2a in chronic active hepatitis B. The International Hepatitis Trial Group. J Viral Hepat. 1994;1(2):139-48. Unapproved itnervention. [pmid: 8790569].
445 Tideman RL, Chen MY, Pitts MK, et al. A randomised controlled trial comparing computer-assisted with face-to-face sexual history taking in a clinical setting. Sex Transm Infect. Feb. 2007;83(1):52-6. Not eligible target population. [pmid: 17098771].
446 Tong NK, Beran J, Kee SA, et al. Immunogenicity and safety of an adjuvanted hepatitis B vaccine in pre-hemodialysis and hemodialysis patients. Kidney Int. Nov. 2005;68(5):2298-303. Not eligible target population. [pmid: 16221232].
447 Toyoda H, Kumada T, Nakano S, et al. Effect of the dose and duration of interferon-alpha therapy on the incidence of hepatocellular carcinoma in noncirrhotic patients with a nonsustained response to interferon for chronic hepatitis C. Oncology. 2001;61(2):134-42. Not eligible target population. [pmid: 11528252].
448 Tozun N, Forbes A, Anderson MG, et al. Safety of alcohol after viral hepatitis. Lancet. May 4. 1991;337(8749):1079-80. Not eligible target population. [pmid: 1673505].
449 Treadwell TL, Keeffe EB, Lake J, et al. Immunogenicity of two recombinant hepatitis B vaccines in older individuals. Am J Med. Dec. 1993;95(6):584-8. Not eligible target population. [pmid: 8259774].
450 Trepo C, Jezek P, Atkinson G, et al. Famciclovir in chronic hepatitis B: results of a dose-finding study. J Hepatol. Jun. 2000;32(6):1011-8. Unapproved itnervention. [pmid: 10898322].
451 Trivello R, Chiaramonte M, Ngatchu T, et al. Persistence of anti-HBs antibodies in health care personnel vaccinated with plasma-derived hepatitis B vaccine and response to recombinant DNA HB booster vaccine. Vaccine. Feb. 1995;13(2):139-41. Not eligible target population. [pmid: 7625106].
452 Truong BX, Seo Y, Kato M, et al. Long-term follow-up of Japanese patients with chronic hepatitis B treated with interferon-alpha. Int J Mol Med. Aug. 2005;16(2):279-84. Case series. [pmid: 16012762].
453 Tsai IJ, Chang MH, Chen HL, et al. Immunogenicity and reactogenicity of the combined hepatitis A and B vaccine in young adults. Vaccine. Oct 15. 2000;19(45):437-41. Not eligible target population. [pmid: 11027806].
454 Tsubota A, Arase Y, Suzuki Y, et al. Lamivudine monotherapy for spontaneous severe acute exacerbation of chronic hepatitis B. J Gastroenterol Hepatol. Mar. 2005;20(3):426-32. Case-series. [pmid: 15740488].
455 Tupasi TE, Co VM, Clarin MS, et al. Randomized, double-blind, placebo-controlled trial of oromucosal low-dose interferon following prednisone withdrawal for chronic hepatitis B infection in Filipino patients. Int J Infect Dis. Mar. 2002;6(1):37-41. Unapproved itnervention. [pmid: 12044300].
456 Turchi MD, Martelli CM, Ferraz ML, et al. Immunogenicity of low-dose intramuscular and intradermal vaccination with recombinant hepatitis B vaccine. Rev Inst Med Trop Sao Paulo. Jan–Feb. 1997;39(1):15-9. Not eligible target population. [pmid: 9394531].
457 ul-Haq N, Hasnain SS, Umar M, et al. Immunogenicity of 10 and 20 microgram hepatitis B vaccine in a two-dose schedule. Vaccine. Jul 4. 2003;21(23):3179-85. Not eligible target population. [pmid: 12804846].
458 Van Damme P, Cramm M, Safary A, et al. Heat stability of a recombinant DNA hepatitis B vaccine. Vaccine. 1992;10(6):366-7. Not eligible target population. [pmid: 1534639].
459 Van der Rijt CC, Schalm SW, Meulstee J, et al. Flumazenil therapy for hepatic encephalopathy. A double-blind cross over study. Gastroenterol Clin Biol. Jun–Jul. 1995;19(67):572-80. Not eligible target population. [pmid: 7590022].
460 Van der Wielen M, Van Damme P, Chlibek R, et al. Hepatitis A/B vaccination of adults over 40 years old: comparison of three vaccine regimens and effect of influencing factors. Vaccine. Jun 29. 2006;24(26):5509-15. Not eligible target population. [pmid: 16725234].
461 Van Herck K, Leroux-Roels G, Van Damme P, et al. Ten-year antibody persistence induced by hepatitis A and B vaccine (Twinrix) in adults. Travel Med Infect Dis. May. 2007;5(3):171-5. Not eligible target population. [pmid: 17448944].
462 Velu V, Nandakumar S, Shanmugam S, et al. Persistence of anti-HBs titers after two different doses of Genevac B, a recombinant hepatitis B vaccine, in healthy adolescents. Indian J Gastroenterol. Jan–Feb. 2007;26(1):48. Not eligible target population.
463 Venkatesan EA, Mathai D, Samuel BU, et al. A comparison of low vs standard dose intramuscularly administered hepatitis B vaccine. J Assoc Physicians India. Jun. 1994;42(6):461-2. Not eligible target population. [pmid: 7852229].
464 Vigano M, Colombo M, Aroldi A, et al. Long-term lamivudine monotherapy in renal-transplant recipients with hepatitis-B-related cirrhosis. Antivir Ther. 2005;10(6):709-13. Case-series. [pmid: 16218169].
465 Vikrant S, Agarwal SK, Gupta S, et al. Prospective randomized control trial of isoniazid chemoprophylaxis during renal replacement therapy. Transpl Infect Dis. Sep–Dec. 2005;7(34):99-108. Not eligible target population. [pmid: 16390397].
466 Villa E, Grottola A, Buttafoco P, et al. High doses of alpha-interferon are required in chronic hepatitis due to coinfection with hepatitis B virus and hepatitis C virus: long term results of a prospective randomized trial. Am J Gastroenterol. Oct. 2001;96(10):2973-7. Unapproved itnervention. [pmid: 11693335].
467 Vincent L, John GT, Abraham P, et al. An intradermal vaccine protocol against hepatitis B in a haemodialysis population. Natl Med J India. Jan–Feb. 1998;11(1):48. Not eligible target population.
468 Vlassopoulos DA, Arvanitis DK, Lilis DS, et al. Lower long-term efficiency of intradermal hepatitis B vaccine compared to the intramuscular route in hemodialysis patients. Int J Artif Organs. Nov. 1999;22(11):739-43. Not eligible target population. [pmid: 10612300].
469 Wang CC, Holte S, Huang ML, et al. Kinetics of hepatitis B viral load during 48 weeks of treatment with 600 mg vs 100 mg of lamivudine daily. J Viral Hepat. Sep. 2004;11(5):443-7. Small sample size. [pmid: 15357650].
470 Wang F, Xu RH, Han B, et al. High incidence of hepatitis B virus infection in B-cell subtype non-Hodgkin lymphoma compared with other cancers. Cancer. Apr 1. 2007;109(7):1360-4. Not eligible target population. [pmid: 17326056].
471 Wang KX, Zhang LH, Peng JL, et al. Effect of liniment levamisole on cellular immune functions of patients with chronic hepatitis B. World J Gastroenterol. Dec 7. 2005;11(45):7208-10. Not eligible exposure. [pmid: 16437674].
472 Wang YJ, Lee SD, Hsieh MC, et al. A double-blind randomized controlled trial of colchicine in patients with hepatitis B virus-related postnecrotic cirrhosis. J Hepatol. Nov. 1994;21(5):872-7. Not eligible exposure. [pmid: 7890905].
473 Weng HL, Wang BE, Jia JD, et al. Effect of interferon-gamma on hepatic fibrosis in chronic hepatitis B virus infection: a randomized controlled study. Clin Gastroenterol Hepatol. Aug. 2005;3(8):819-28. Not eligible exposure. [pmid: 16234012].
474 Westblom TU, Gudipati S, DeRousse C, et al. Safety and immunogenicity of an inactivated hepatitis A vaccine: effect of dose and vaccination schedule. J Infect Dis. May. 1994;169(5):996-1001. Not eligible target population. [pmid: 8169430].
475 Whittle H, Jaffar S, Wansbrough M, et al. Observational study of vaccine efficacy 14 years after trial of hepatitis B vaccination in Gambian children. BMJ. Sep 14. 2002;325(7364):569. Not eligible target population. [pmid: 12228132].
476 Whittle HC, Inskip H, Hall AJ, et al. Vaccination against hepatitis B and protection against chronic viral carriage in The Gambia. Lancet. Mar 30. 1991;337(8744):747-50. Not eligible target population. [pmid: 1672389].
477 Whittle HC, Maine N, Pilkington J, et al. Long-term efficacy of continuing hepatitis B vaccination in infancy in two Gambian villages. Lancet. Apr 29. 1995;345(8957):1089-92. Not eligible target population. [pmid: 7715343].
478 Wiedermann U, Kundi M, Vollmann U, et al. Different HBs antibody versus lymphoproliferative responses after application of a monovalent (hepatitis B) or combined (hepatitis A + hepatitis B) vaccine. Int Arch Allergy Immunol. Dec. 2000;123(4):349-53. Not eligible target population. [pmid: 11146393].
479 Williams JL, Christensen CJ, McMahon BJ, et al. Evaluation of the response to a booster dose of hepatitis B vaccine in previously immunized healthcare workers. Vaccine. Jul 16. 2001;19(2829):4081-5. Not eligible target population. [pmid: 11427285].
480 Williams SJ, Craig PI, Cooksley WG, et al. Randomised controlled trial of recombinant human interferon -alpha A for chronic active hepatitis B. Aust N Z J Med. Feb. 1990;20(1):9-19. Unapproved itnervention. [pmid: 2181991].
481 Williamson LM, Llewelyn CA, Fisher NC, et al. A randomized trial of solvent/detergent-treated and standard fresh-frozen plasma in the coagulopathy of liver disease and liver transplantation. Transfusion. Nov–Dec. 1999;39(1112):1227-34. Not eligible target population. [pmid: 10604250].
482 Winter AP, Follett EA, McIntyre J, et al. Influence of smoking on immunological responses to hepatitis B vaccine. Vaccine. Jul. 1994;12(9):771-2. Not eligible target population. [pmid: 7975854].
483 Wistrom J, Ahlm C, Lundberg S, et al. Booster vaccination with recombinant hepatitis B vaccine four years after priming with one single dose. Vaccine. Apr 23. 1999;17(17):2162-5. Not eligible target population. [pmid: 10367949].
484 Wistrom J, Settergren B, Gustafsson A, et al. Intradermal vs intramuscular hepatitis B vaccinations. JAMA. Jul 11. 1990;264(2):181-2. Letter. [pmid: 2141364].
485 Wolf HH, Davies SV, Borte M, et al. Efficacy, tolerability, safety and pharmacokinetics of a nanofiltered intravenous immunoglobulin: studies in patients with immune thrombocytopenic purpura and primary immunodeficiencies. Vox Sang. Jan. 2003;84(1):45-53. Not eligible target population. [pmid: 12542733].
486 Wolters LM, Hansen BE, Niesters HG, et al. Viral dynamics in chronic hepatitis B patients treated with lamivudine, lamivudine-famciclovir or lamivudine-ganciclovir. Eur J Gastroenterol Hepatol. Sep. 2002;14(9):1007-11. Unapproved itnervention. [pmid: 12352221].
487 Wolters LM, Hansen BE, Niesters HG, et al. The influence of baseline characteristics on viral dynamic parameters in chronic hepatitis B patients treated with lamivudine. J Hepatol. Aug. 2002;37(2):253-8. Small sample size. [pmid: 12127431].
488 Wolters LM, van Nunen AB, Niesters HG, et al. Contrasting patterns of response to lamivudine monotherapy in chronic hepatitis B patients. Scand J Gastroenterol Suppl 2000; (232):74–8. Case-series
489 Wong DK, Yim C, Naylor CD, et al. Interferon alfa treatment of chronic hepatitis B: randomized trial in a predominantly homosexual male population. Gastroenterology. Jan. 1995;108(1):165-71. Unapproved itnervention. [pmid: 7806038].
490 Wong JB. Interferon treatment for chronic hepatitis B or C infection: costs and effectiveness. Acta Gastroenterol Belg. Apr–Jun. 1998;61(2):238-42. Not eligible outcomes. [pmid: 9658620].
491 Wong VW, Chan HL, Wong ML, et al. Clinical course after stopping lamivudine in chronic hepatitis B patients with lamivudine-resistant mutants. Aliment Pharmacol Ther. Feb 1. 2004;19(3):323-9. Small sample size. [pmid: 14984379].
492 Wouters K, Leuridan E, Van Herck K, et al. Compliance and immunogenicity of two hepatitis B vaccination schedules in sex workers in Belgium. Vaccine. Feb 26. 2007;25(10):1893-900. Not eligible target population. [pmid: 17239492].
493 Wursthorn K, Lutgehetmann M, Dandri M, et al. Peginterferon alpha-2b plus adefovir induce strong cccDNA decline and HBsAg reduction in patients with chronic hepatitis B. Hepatology. Sep. 2006;44(3):675-84. Case-series. [pmid: 16941693].
494 Xin-Hua W, Chang-Qing L, Xing-Bo G, et al. A comparative study of Phyllanthus amarus compound and interferon in the treatment of chronic viral hepatitis B. Southeast Asian J Trop Med Public Health. Mar. 2001;32(1):140-2. Not eligible exposure. [pmid: 11485076].
495 Yalcin K, Acar M, Degertekin H. Specific hepatitis B vaccine therapy in inactive HBsAg carriers: a randomized controlled trial. Infection. Aug. 2003;31(4):221-5. Unapproved itnervention. [pmid: 14562945].
496 Yalcin K, Danis R, Degertekin H, et al. The lack of effect of therapeutic vaccination with a pre-S2/S HBV vaccine in the immune tolerant phase of chronic HBV infection. J Clin Gastroenterol. Oct. 2003;37(4):330-5. Unapproved itnervention. [pmid: 14506391].
497 Yalcin K, Degertekin H, Kokoglu OF, et al. A three-month course of lamivudine therapy in HBeAg-positive hepatitis B patients with normal aminotransferase levels. Turk J Gastroenterol. Mar. 2004;15(1):14-20. Small sample size. [pmid: 15264116].
498 Yamanaka N, Tanaka T, Tanaka W, et al. Correlation of hepatitis virus serologic status with clinicopathologic features in patients undergoing hepatectomy for hepatocellular carcinoma. Cancer. Apr 15. 1997;79(8):1509-15. Not eligible target population. [pmid: 9118031].
499 Yamashiki M, Kosaka Y, Nishimura A. An effective intradermal hepatitis B vaccination. Vaccine. Oct. 1997;15(15):1618-23. Not eligible target population. [pmid: 9364692].
500 Yang HZ, Zhao JA, Dai M, et al. Traditional Chinese medicine syndromes of chronic hepatitis B with precore mutant. World J Gastroenterol. Apr 7. 2005;11(13):2004-8. Not eligible outcomes. [pmid: 15800995].
501 Yang SS, Hsu CT, Hu JT, et al. Lamivudine does not increase the efficacy of interferon in the treatment of mutant type chronic viral hepatitis B. World J Gastroenterol. Oct. 2002;8(5):868-71. Case-series. [pmid: 12378632].
502 Yao G, Cui Z, Wang B, et al. An extended two-year trial of lamivudine in Chinese patients with chronic hepatitis B. Chin Med J (Engl). Dec. 2002;115(12):1814-8. RCT reportes as case-series. [pmid: 12622930].
503 Yao GB, Cui ZY, Wang BE, et al. A 3-year clinical trial of lamivudine in treatment of patients with chronic hepatitis B. Hepatobiliary Pancreat Dis Int. May. 2004;3(2):188-93. RCT reported as case-series. [pmid: 15138107].
504 Yap I, Guan R, Chan SH. Recombinant DNA hepatitis B vaccine containing Pre-S components of the HBV coat protein—a preliminary study on immunogenicity. Vaccine. 1992;10(7):439-42. Not eligible target population. [pmid: 1535170].
505 Yap I, Guan R, Chan SH. Study on the comparative immunogenicity of a recombinant DNA hepatitis B vaccine containing pre-S components of the HBV coat protein with non pre-S containing vaccines. J Gastroenterol Hepatol. Jan–Feb. 1995;10(1):51-5. Not eligible target population. [pmid: 7620108].
506 Yeh CT, Sheen IS, Chen TC, et al. Prednisolone modulates the therapeutic effect of interferon to eliminate preferentially the hepatitis B virus precore stop mutant. J Hepatol. May. 2000;32(5):829-36. Unapproved itnervention. [pmid: 10845671].
507 Yeo W, Lam KC, Zee B, et al. Hepatitis B reactivation in patients with hepatocellular carcinoma undergoing systemic chemotherapy. Ann Oncol. Nov. 2004;15(11):1661-6. Not eligible exposure. [pmid: 15520068].
508 Yeo W, Mo FK, Chan SL, et al. Hepatitis B viral load predicts survival of HCC patients undergoing systemic chemotherapy. Hepatology. Jun. 2007;45(6):1382-9. Not eligible exposure. [pmid: 17539025].
509 Yeung YP, Lo CM, Liu CL, et al. Natural history of untreated nonsurgical hepatocellular carcinoma. Am J Gastroenterol. Sep. 2005;100(9):1995-2004. Not eligible target population. [pmid: 16128944].
510 Yoo BC, Kim JH, Chung YH, et al. Twenty-four-week clevudine therapy showed potent and sustained antiviral activity in HBeAg-positive chronic hepatitis B. Hepatology. May. 2007;45(5):1172-8. Unapproved itnervention. [pmid: 17464992].
511 You J, Zhuang L, Cheng HY, et al. A randomized, controlled, clinical study of thymosin alpha-1 versus interferon-alpha in [corrected] patients with chronic hepatitis B lacking HBeAg in China [corrected]. J Chin Med Assoc. Feb. 2005;68(2):65-72. Unapproved itnervention. [pmid: 15759817].
512 You J, Zhuang L, Cheng HY, et al. Efficacy of thymosin alpha-1 and interferon alpha in treatment of chronic viral hepatitis B: a randomized controlled study. World J Gastroenterol. Nov 7. 2006;12(41):6715-21. Unapproved itnervention. [pmid: 17075991].
513 You J, Zhuang L, Tang BZ, et al. A randomized controlled clinical trial on the treatment of Thymosin a1 versus interferon-alpha in patients with hepatitis B. World J Gastroenterol. Jun. 2001;7(3):411-4. Unapproved itnervention. [pmid: 11819801].
514 Young MD, Gooch WM 3rd, Zuckerman AJ, et al. Comparison of a triple antigen and a single antigen recombinant vaccine for adult hepatitis B vaccination. J Med Virol. Jul. 2001;64(3):290-8. Not eligible target population. [pmid: 11424117].
515 Young MD, Rosenthal MH, Dickson B, et al. A multi-center controlled study of rapid hepatitis B vaccination using a novel triple antigen recombinant vaccine. Vaccine. May 14. 2001;19(2526):3437-43. Not eligible target population. [pmid: 11348708].
516 Young MD, Schneider DL, Zuckerman AJ, et al. Adult hepatitis B vaccination using a novel triple antigen recombinant vaccine. Hepatology. Aug. 2001;34(2):372-6. Not eligible target population. [pmid: 11481622].
517 Yu SY, Zhu YJ, Li WG. Protective role of selenium against hepatitis B virus and primary liver cancer in Qidong. Biol Trace Elem Res. Jan. 1997;56(1):117-24. Not eligible exposure. [pmid: 9152515].
518 Yu SY, Zhu YJ, Li WG, et al. A preliminary report on the intervention trials of primary liver cancer in high-risk populations with nutritional supplementation of selenium in China. Biol Trace Elem Res. Jun. 1991;29(3):289-94. Not eligible exposure. [pmid: 1726411].
519 Yu YS, Tang ZH, Han JC, et al. Expression of ICAM-1, HLA-DR, and CD80 on peripheral circulating CD1 alpha DCs induced in vivo by IFN-alpha in patients with chronic hepatitis B. World J Gastroenterol. Mar 7. 2006;12(9):1447-51. Not eligible outcomes. [pmid: 16552819].
520 Yuan J, Lin J, Xu A, et al. Antepartum immunoprophylaxis of three doses of hepatitis B immunoglobulin is not effective: a single-centre randomized study. J Viral Hepat. Sep. 2006;13(9):597-604. Not eligible target population. [pmid: 16907846].
521 Yue Y, Yang X, Zhang S. Prevention of intrauterine infection by hepatitis B virus with hepatitis B immune globulin: efficacy and mechanism. Chin Med J (Engl). Jan. 1999;112(1):37-9. Not eligible target population. [pmid: 11593638].
522 Yuen GJ, Morris DM, Mydlow PK, et al. Pharmacokinetics, absolute bioavailability, and absorption characteristics of lamivudine. J Clin Pharmacol. Dec. 1995;35(12):1174-80. Not eligible outcomes. [pmid: 8750368].
523 Yuen MF, Hui CK, Cheng CC, et al. Long-term follow-up of interferon alfa treatment in Chinese patients with chronic hepatitis B infection: The effect on hepatitis B e antigen seroconversion and the development of cirrhosis-related complications. Hepatology. Jul. 2001;34(1):139-45. Unapproved itnervention. [pmid: 11431745].
524 Yuen MF, Kim J, Kim CR, et al. A randomized placebo-controlled, dose-finding study of oral LB80380 in HBeAg-positive patients with chronic hepatitis B. Antivir Ther. 2006;11(8):977-83. Unapproved itnervention. [pmid: 17302367].
525 Yuen MF, Sablon E, Hui CK, et al. Factors associated with hepatitis B virus DNA breakthrough in patients receiving prolonged lamivudine therapy. Hepatology. Oct. 2001;34(4 Pt 1):785-91. RCT reported as case-series. [pmid: 11584376].
526 Yuen MF, Wong DK, Sum SS, et al. Effect of lamivudine therapy on the serum covalently closed-circular (ccc) DNA of chronic hepatitis B infection. Am J Gastroenterol. May. 2005;100(5):1099-103. Not eligible outcomes. [pmid: 15842584].
527 Yurdaydin C, Bozkaya H, Cetinkaya H, et al. Lamivudine vs lamivudine and interferon combination treatment of HBeAg(-) chronic hepatitis B. J Viral Hepat. May. 2005;12(3):262-8. Unapproved itnervention. [pmid: 15850466].
528 Zarski JP, Barange K, Souvignet C, et al. Efficacy and safety of lactosaminated human serum albumin-adenine arabinoside monophosphate in chronic hepatitis B patients non-responders to interferon therapy: a randomised clinical trial. J Hepatol. Mar. 2001;34(3):486-8. Letter. [pmid: 11322216].
529 Zavaglia C, Bottelli R, Bellati G, et al. Treatment of chronic hepatitis B (HBeAg-HBV DNA-positive) with lymphoblastoid alpha interferon with or without corticosteroids: short- and long-term follow-up. Ital J Gastroenterol. Jul–Aug. 1996;28(6):324-31. Unapproved itnervention. [pmid: 8891847].
530 Zavaglia C, Severini R, Tinelli C, et al. A randomized, controlled study of thymosin-alpha1 therapy in patients with anti-HBe, HBV-DNA-positive chronic hepatitis B. Dig Dis Sci. Apr. 2000;45(4):690-6. Unapproved itnervention. [pmid: 10759236].
531 Zeuzem S, Carreno V. Interleukin-12 in the treatment of chronic hepatitis B and C. Antiviral Res. Nov. 2001;52(2):181-8. Not eligible exposure. [pmid: 11672828].
532 Zhang B, Yang B. Combined alpha fetoprotein testing and ultrasonography as a screening test for primary liver cancer. J Med Screen. 1999;6(2):108-10. Not eligible exposure. [pmid: 10444731].
533 Zhang BH, Yang BH, Tang ZY. Randomized controlled trial of screening for hepatocellular carcinoma. J Cancer Res Clin Oncol. Jul. 2004;130(7):417-22. Not eligible exposure. [pmid: 15042359].
534 Zhang CP, Tian ZB, Liu XS, et al. Effects of Zhaoyangwan on chronic hepatitis B and posthepatic cirrhosis. World J Gastroenterol. Jan 15. 2004;10(2):295-8. Not eligible exposure. [pmid: 14716843].
535 Zhang H, Yang X, Zhu S. [Side effects after treatment with a-interferon in children with chronic viral hepatitis]. Zhonghua Shi Yan He Lin Chuang Bing Du Xue Za Zhi. Dec. 2000;14(4):376-8. Not eligible target population. [pmid: 11471032].
536 Zhang SJ, Chen ZX, Lao SX, et al. Effect of Hejie decoction on T cell immune state of chronic hepatitis B patients. World J Gastroenterol. May 15. 2004;10(10):1436-9. Not eligible exposure. [pmid: 15133849].
537 Zhou XJ, Lim SG, Lloyd DM, et al. Pharmacokinetics of telbivudine following oral administration of escalating single and multiple doses in patients with chronic hepatitis B virus infection: pharmacodynamic implications. Antimicrob Agents Chemother. Mar. 2006;50(3):874-9. Not eligible outcomes. [pmid: 16495245].
538 Zhou XJ, Lloyd DM, Chao GC, et al. Absence of food effect on the pharmacokinetics of telbivudine following oral administration in healthy subjects. J Clin Pharmacol. Mar. 2006;46(3):275-81. Not eligible target population. [pmid: 16490803].
539 Zhu Q, Lu Q, Gu X, et al. A preliminary study on interruption of HBV transmission in uterus. Chin Med J (Engl). Feb. 1997;110(2):145-7. Not eligible target population. [pmid: 9594288].
540 Zhu Q, Yu G, Yu H, et al. A randomized control trial on interruption of HBV transmission in uterus. Chin Med J (Engl). May. 2003;116(5):685-7. Not eligible target population. [pmid: 12875680].
541 Zhu XX, Pan CY, Li GW, et al. Addition of rosiglitazone to existing sulfonylurea treatment in chinese patients with type 2 diabetes and exposure to hepatitis B or C. Diabetes Technol Ther. 2003;5(1):33-42. Not eligible target population. [pmid: 12725705].
542 Zhuang L, You J, Tang BZ, et al. Preliminary results of Thymosin-a1 versus interferon-alpha-treatment in patients with HBeAg negative and serum HBV DNA positive chronic hepatitis B. World J Gastroenterol. Jun. 2001;7(3):407-10. Unapproved itnervention. [pmid: 11819800].
543 Zografos TA, Rigopoulou EI, Liaskos C, et al. Alterations of leptin during IFN-alpha therapy in patients with chronic viral hepatitis. J Hepatol. May. 2006;44(5):848-55. Not eligible outcomes. [pmid: 16530290].
544 Zuberi BF, Quraishy MS, Afsar S, et al. Treatment outcome in patients of hepatitis B with hepatitis D: experience of 4 years at a tertiary care centre in Pakistan. J Coll Physicians Surg Pak. Jun. 2007;17(6):320-2. Case-series. [pmid: 17623577].
545 Zuberi BF, Rajput MR, Muzaffar L, et al. Efficacy of low dose intra-dermal hepatitis B vaccination schedule. J Pak Med Assoc. Dec. 1998;48(12):377-8. Not eligible target population. [pmid: 10531773].
546 Zuckerman JN, Sabin C, Craig FM, et al. Immune response to a new hepatitis B vaccine in healthcare workers who had not responded to standard vaccine: randomised double blind dose-response study. BMJ. Feb 1. 1997;314(7077):329-33. Not eligible target population. [pmid: 9040320].
547 Zuckerman JN, Zuckerman AJ, Symington I, et al. Evaluation of a new hepatitis B triple-antigen vaccine in inadequate responders to current vaccines. Hepatology. Oct. 2001;34(4 Pt 1):798-802. Not eligible target population. [pmid: 11584378].