# Appendix A. Exact Search Strings

## Key Question 1 - literature search string

Database: Ovid MEDLINE(R)

Medical Subject Heading Terms | | Number of Retrieved References
1 | Exp Hepatitis B, chronic/ or exp Hepatitis B/ or exp Hepatitis B virus/ | 39,405
2 | Exp hepatocellular carcinoma | 40,097
3 | Exp liver failure | 12,710
4 | Liver cirrhosis.mp. or exp liver cirrhosis | 59,664
5 | Liver cirrhosis.mp. or exp liver cirrhosis/ | 393,300
6 | Exp Death/ or death.mp | 366,266
7 | Exp Survival/ or survival.mp. or exp survival rate | 480,039
8 | or/2–7 | 1,076,543
9 | Natural history/ or cohort studies/ or prospective studies/ or longitudinal studies/ or cohort.mp. or prospective.mp. or longitudinal.mp. | 491,684
10 | 1 and 8 and 9 | 621
11 | Limit 10 to (humans and English language) | 558

## Key Questions 2–4 - literature search strings

Medical Subject Heading Terms | Number of Retrieved References
“Hepatitis B, Chronic”[Mesh] NOT review NOT Case Reports Limits: Humans, Journal Article, English, All Adult: 19+ years | 1,525
“Hepatitis B, Chronic”[Mesh] Limits: Publication Date from 1990/01/01 to 2007/12/31, Humans, Journal Article, English, All Adult: 19+ years | 1,778
“Hepatitis B, Chronic”[Mesh] | 4,329
“Hepatitis B, Chronic”[Mesh] Limits: Humans, Randomized Controlled Trial, English, All Adult: 19+ years | 182
“Hepatitis B” Limits: Humans, Randomized Controlled Trial, English, All Adult: 19+ years | 712
(“Hepatitis B, Chronic/prevention and control”[Mesh] OR “Hepatitis B, Chronic/therapy”[Mesh]) AND “Epidemiologic studies” [Mesh] Limits: Humans, English, All Adult: 19+ years | 286
(“Hepatitis B, Chronic/prevention and control”[Mesh] OR “Hepatitis B, Chronic/therapy”[Mesh]) Limits: Humans, English, All Adult: 19+ years | 855
“Hepatitis B, Chronic”[Mesh] Limits: Humans, English, All Adult: 19+ years AND (“Interferons/drug effects”[Mesh] OR “Interferons/metabolism”[Mesh] OR “Interferons/pharmacokinetics”[Mesh] OR “Interferons/pharmacology”[Mesh] OR “Interferons/poisoning”[Mesh] OR “Interferons/therapeutic use”[Mesh]) Limits: Humans, Controlled Clinical Trial, English, All Adult: 19+ years | 14
(“Interferons/drug effects”[Mesh] OR “Interferons/metabolism”[Mesh] OR “Interferons/pharmacokinetics”[Mesh] OR “Interferons/pharmacology”[Mesh] OR “Interferons/poisoning”[Mesh] OR “Interferons/therapeutic use”[Mesh]) Limits: Humans, Controlled Clinical Trial, English, All Adult: 19+ years | 398
“Hepatitis B, Chronic”[Mesh] Limits: Humans, Controlled Clinical Trial, English, All Adult: 19+ years | 35
“Hepatitis B, Chronic”[Mesh] Limits: Humans, Clinical Trial, Phase IV, English, All Adult: 19+ years | 0
“Hepatitis B, Chronic”[Mesh] Limits: Humans, Clinical Trial, Phase III, English, All Adult: 19+ years | 16
“Hepatitis B, Chronic”[Mesh] Limits: Humans, Clinical Trial, Phase I, Clinical Trial, Phase II, English, All Adult: 19+ years | 23
“Hepatitis B, Chronic”[Mesh] Limits: Humans, Clinical Trial, Phase I, English, All Adult: 19+ years | 10
“Adefovir” [Substance Name] AND “hepatitis B” Limits: Entrez Date from 1990/01/01 to 2007/12/31, Humans, Randomized Controlled Trial, English, All Adult: 19+ years | 1
“Adefovir” [Substance Name] Limits: Entrez Date from 1990/01/01 to 2007/12/31, Humans, Randomized Controlled Trial, English, All Adult: 19+ years | 6
“Entecavir” [Substance Name] AND “hepatitis B” Limits: Entrez Date from 1990/01/01 to 2007/12/31, Humans, Randomized Controlled Trial, English, All Adult: 19+ years | 5
“Entecavir” [Substance Name] Limits: Entrez Date from 1990/01/01 to 2007/12/31, Humans, Randomized Controlled Trial, English, All Adult: 19+ years | 6
“Telbivudine” [Substance Name] AND “hepatitis B” Limits: Entrez Date from 1990/01/01 to 2007/12/31, Humans, Randomized Controlled Trial, English, All Adult: 19+ years | 4
“Telbivudine” [Substance Name] Limits: Entrez Date from 1990/01/01 to 2007/12/31, Humans, Randomized Controlled Trial, English, All Adult: 19+ years | 4
“Interferons”[Mesh] AND “hepatitis B” Limits: Entrez Date from 1990/01/01 to 2007/12/31, Humans, Randomized Controlled Trial, English, All Adult: 19+ years | 169
“Hepatitis B, Chronic”[Mesh] AND “Effect Modifiers (Epidemiology)”[Mesh] Limits: Humans, English, All Adult: 19+ years | 1
“Hepatitis B, Chronic” AND “Treatment Outcome”[Mesh] AND “Effect Modifiers (Epidemiology)”[Mesh] Limits: Humans, English, All Adult: 19+ years | 1
“Hepatitis B, Chronic”[Mesh] AND “Treatment Outcome”[Mesh] AND “Effect Modifiers (Epidemiology)”[Mesh] Limits: Humans, English, All Adult: 19+ years | 1
“Epidemiologic studies”[Mesh] AND “Biological Factors”[Mesh] AND (“Hepatitis B, Chronic/prevention and control”[Mesh] OR “Hepatitis B, Chronic/therapy”[Mesh]) Limits: Humans, English, All Adult: 19+ years | 202
“Biological Factors”[Mesh] AND (“Hepatitis B, Chronic/prevention and control”[Mesh] OR “Hepatitis B, Chronic/therapy”[Mesh]) Limits: Humans, English, All Adult: 19+ years | 576
“Disease Progression”[Mesh] AND (“Hepatitis B, Chronic/prevention and control”[Mesh] OR “Hepatitis B, Chronic/therapy”[Mesh]) Limits: Humans, English, All Adult: 19+ years | 17
Update January 7, 2008
“Hepatitis B, Chronic”[Mesh] Limits: Publication Date from 2007/11/01 to 2008/3/31, Humans, Randomized Controlled Trial, English, All Adult: 19+ years | 3