# Appendixes

Appendix A. Exact Search Strings

Appendix B. List of Excluded Studies

Appendix C. Technical Expert Panel Members and Affiliation

Appendix D. Analytic Framework

Appendix E Tables and Figures

Appendix F. Data Abstraction Form