# Appendixes

Appendix A: Technical Expert Panel Members and Affiliation

Appendix B: Search String

Appendix C: Data Abstraction Form

Appendix D: Patient Inclusion and Exclusion Criteria

Appendix E: Evidence Table

Appendix F: List of Excluded Studies