# Appendix F: List of Excluded Studies

## References

1 Abbotts J, Williams R, Ford G, et al. Morbidity and Irish Catholic descent in Britain: relating health disadvantage to behaviour. Ethnicity & Health. Nov. 1999;4(4):221-30. Not mental health condition. [pmid: 10705559].
2 Absi EG, Satterthwaite J, Shepherd JP, et al. The appropriateness of referral of medically compromised dental patients to hospital. British Journal of Oral & Maxillofacial Surgery. Apr. 1997;35(2):133-6. Not mental health condition. [pmid: 9146873].
3 Addo J, Amoah AG, Koram KA. The changing patterns of hypertension in Ghana: a study of four rural communities in the Ga District. Ethnicity & Disease. 2006;16(4):894-9. Not mental health condition. [pmid: 17061743].
4 Adeyemi JD, Olonade PO, Amira CO. Attitude to Psychiatric Referral: A study of Primary Care Physicians Nigerian Postgraduate. Medical Journal. Jun. 2002;9(2):53-8. Not integrated care.
5 Advani N, Menahem S, Wilkinson JL. The diagnosis of innocent murmurs in childhood. Cardiology in the Young. Oct. 2000;10(4):340-2. Not mental health condition. [pmid: 10950330].
6 Aggarwal G, Glare P, Clarke S, et al. Palliative and shared care concepts in patients with advanced colorectal cancer. ANZ Journal of Surgery. Mar. 2006;76(3):175-80. Not primary care setting. [pmid: 16626361].
7 Ajiboye PO, Adelekan ML. A prospective analysis of in-patient consultation-liaison psychiatry in a Nigerian teaching hospital. East African Medical Journal. Dec. 2004;81(12):620-5. International. [pmid: 15868976].
8 Alhamad AM. Pattern of gastroenterology psychiatric consultations. A prospective study Saudi Medical Journal. Sep. 2004;25(9):1284-6. International. [pmid: 15448790].
9 Al-Jaddou H, Malkawi A. Prevalence, recognition and management of mental disorders in primary health care in Northern. Jordan Acta Psychiatrica Scandinavica. Jul. 1997;96(1):31-5. Not integrated care. [pmid: 9259221].
10 Allen CM, Becker PM, McVey LJ, et al. A randomized, controlled clinical trial of a geriatric consultation team. Compliance with recommendations JAMA. May 16. 1986;255(19):2617-21. Not primary care setting. [pmid: 3517396].
11 Allen KR, Hazelett S, Jarjoura D, et al. Effectiveness of a postdischarge care management model for stroke and transient ischemic attack: a randomized trial. Journal of Stroke and Cerebrovascular Diseases. Mar–Apr. 2002;11(2):88-98. Not mental health condition. [pmid: 17903862].
12 Ambrogne JA. Managing depressive symptoms in the context of abstinence: findings from a qualitative study of women. Perspectives in Psychiatric Care. Apr. 2007;43(2):84-92. Not integrated care. [pmid: 17388851].
13 Ames D, Flicker L, Helme RD. A memory clinic at a geriatric hospital: rationale, routine and results from the first 100 patients. Medical Journal of Australia. May 4. 1992;156(9):618-22. Not primary care setting. [pmid: 1625615].
14 Andersen M, Hockman E, Smereck G, et al. Retaining women in HIV medical care. Journal of the Association of Nurses in AIDS Care. May–Jun. 2007;18(3):33-41. Not mental health condition. [pmid: 17570298].
15 Andersen M, Paliwoda J, Kaczynski R, et al. Integrating medical and substance abuse treatment for addicts living with HIV/AIDS: evidence-based nursing practice model. American Journal of Drug & Alcohol Abuse. 2003;29(4):847-59. Not primary care setting. [pmid: 14713143].
16 Andersen MD, Smereck GA, Hockman EM, et al. Nurses decrease barriers to health care by “hyperlinking” multiple-diagnosed women living with HIV/AIDS into care. Journal of the Association of Nurses in AIDS Care. Mar–Apr. 1999;10(2):55-65. Not mental health condition. [pmid: 10065410].
17 Andersen SM, Harthorn BH. Changing the psychiatric knowledge of primary care physicians. The effects of a brief intervention on clinical diagnosis and treatment. General Hospital Psychiatry. May. 1990;12(3):177-90. Not integrated care. [pmid: 2335304].
18 Andrea H, Kant IJ, Beurskens AJ, et al. Associations between fatigue attributions and fatigue, health, and psychosocial work characteristics: a study among employees visiting a ptitlewith fatigue. Occupational & Environmental Medicine. Jun. 2003;60(Suppl 1):i99-104. Not mental health condition. [pmid: 12782755].
19 Andrews G. ClimateGP - web based patient education. Australian Family Physician. May. 2007;36(5):371-2. Not mental health condition. [pmid: 17492076].
20 Anonymous. Effectiveness of routine self monitoring of peak flow in patients with asthma. Grampian Asthma Study of Integrated Care (GRASSIC).[see comment] BMJ 1994 Feb 26; 308(6928):564–7. Not mental health condition
21 Anonymous. Integrated care for asthma: a clinical, social, and economic evaluation. Grampian Asthma Study of Integrated Care (GRASSIC)[see comment] BMJ 1994 Feb 26; 308(6928):559–64. Not integrated care
22 Anonymous. Auditory integration training and facilitated communication for autism. American Academy of Pediatrics. Committee on Children with Disabilities Pediatrics 1998 Aug; 102(2 Pt 1):431–3. Not primary care setting
23 Anonymous. Collaborative care models for the treatment of depression. Based on a presentation by Wayne Katon, MD. American Journal of Managed Care 1999 Sep; 5(13 Suppl):S794–800; discussion S-10. Not on target, other publication type
24 Anonymous. Researchers hot on the trail of modest interventions to boost depression care Disease Management Advisor 2001 Jul; 7(7):107–10. Not on target, other publication type
25 Aoun S. Methodological considerations for a psychosocial illness survey in general practice. Australian Journal of Rural Health. Aug. 1997;5(3):140-6. Not integrated care. [pmid: 9437941].
26 Appleton PL, Boll V, Everett JM, et al. Beyond child development centres: care coordination for children with disabilities. Child: Care, Health & Development. Jan. 1997;23(1):29-40. Not mental health condition.
27 Armstrong MA, Lieberman L, Carpenter DM, et al. Early Start: an obstetric clinic-based, perinatal substance abuse intervention program. Quality Management in Health Care. 2001;9(2):6-15. Not integrated care. [pmid: 14598626].
28 Arnold IA, Speckens AE, van Hemert AM. Medically unexplained physical symptoms: the feasibility of group cognitive-behavioural therapy in primary care. Journal of Psychosomatic Research. Dec. 2004;57(6):517-20. International. [pmid: 15596157].
29 Ashworth M. Effect of on-site mental health professionals. Longer trials are needed. [comment]. BMJ. Sep 16. 2000;321(7262):701-2. Not on target, other publication type. [pmid: 11202930].
30 Ashworth M, Clement S, Sandhu J, et al. Can psychiatric liaison reduce neuroleptic use and reduce health service utilization for dementia patients residing in care facilities. British Journal of General Practice. Jan. 2002;52(474):39-41. International. [pmid: 11791814].
31 Au S, Hiew S. Integrating Western medicine and Traditional Chinese medicine in GP surgeries and the community: a review of the two pilot schemes. Journal of the Royal Society of Health. Dec. 2002;122(4):220-5. Not mental health condition.
32 Austrom MG, Hartwell C, Moore PS, et al. A care management model for enhancing physician practice for Alzheimer disease in primary care. Clinical Gerontologist. 2006;29(2):35-43. Not included study design.
33 Badcock LJ, Lewis M, Hay EM, et al. Consultation and the outcome of shoulder-neck pain: a cohort study in the population. Journal of Rheumatology. Dec. 2003;30(12):2694-9. Not mental health condition. [pmid: 14719215].
34 Badger LW, Rand EH. Unlearning psychiatry: a cohort effect in the training environment. International Journal of Psychiatry in Medicine. 1988;18(2):123-35. Not integrated care. [pmid: 3170079].
35 Bagg J, Sweeney CP, Roy KM, et al. Cross infection control measures and the treatment of patients at risk of Creutzfeldt Jakob disease in UK general dental practice.[see comment]. British Dental Journal. Jul 28. 2001;191(2):87-90. Not mental health condition. [pmid: 11508417].
36 Bailey G, Hyde L, Morton R. Sending a copy of the letter to the general practitioner also to the parents in a child development centre: does it work?. Child: Care, Health & Development. Nov. 1996;22(6):411-9. Not mental health condition.
37 Baker D, Mead N, Campbell S. Inequalities in morbidity and consulting behaviour for socially vulnerable groups. British Journal of General Practice. Feb. 2002;52(475):124-30. Not integrated care. [pmid: 11885821].
38 Bakker IM, Terluin B, van Marwijk HW, et al. Effectiveness of a Minimal Intervention for Stress-related mental disorders with Sick leave (MISS); study protocol of a cluster randomised controlled trial in general practice [ISRCTN43779641]. BMC Public Health. 2006;6:124. International. [pmid: 16674806].
39 Balabanova D, McKee M, Pomerleau J, et al. Health service utilization in the former soviet union: evidence from eight countries. Health Services Research. Dec. 2004;39(6 Pt 2):1927-50. Not mental health condition. [pmid: 15544638].
40 Baldwin PJ, Dodd M, Wrate RM. Young doctors' health—II. Health and health behaviour. Social Science & Medicine. Jul. 1997;45(1):41-4. Not integrated care. [pmid: 9203269].
41 Ballard C, Powell I, James I, et al. Can psychiatric liaison reduce neuroleptic use and reduce health service utilization for dementia patients residing in care facilities. International Journal of Geriatric Psychiatry. Feb. 2002;17(2):140-5. Not primary care setting. [pmid: 11813276].
42 Bambauer KZ, Soumerai SB, Adams AS, et al. Provider and patient characteristics associated with antidepressant nonadherence: the impact of provider specialty. Journal of Clinical Psychiatry. Jun. 2007;68(6):867-73. Not integrated care. [pmid: 17592910].
43 Bambling M, Kavanagh D, Lewis G, et al. Challenges faced by general practitioners and allied mental health services in providing mental health services in rural. Queensland Australian Journal of Rural Health. Apr. 2007;15(2):126-30. Not integrated care. [pmid: 17441822].
44 Bandla H, Franco R, Statza T, et al. Integrated selective: an innovative teaching strategy for sleep medicine instruction for medical students. Sleep Medicine. Mar. 2007;8(2):144-8. Not mental health condition. [pmid: 17275403].
45 Barbui C, Motterlini N, Garattini L, et al. Health status, resource consumption, and costs of dysthymia. A multi-center two-year longitudinal study. Journal of Affective Disorders. Feb. 2006;90(23):181-6. Not integrated care. [pmid: 16352344].
46 Barnes S, Gott M, Payne S, et al. Characteristics and views of family carers of older people with heart failure. International Journal of Palliative Nursing. Aug. 2006;12(8):380-9. Not mental health condition. [pmid: 17077796].
47 Barr W. Characteristics of severely mentally ill patients in and out of contact with community mental health services. Journal of Advanced Nursing. May. 2000;31(5):1189-98. Not integrated care. [pmid: 10840253].
48 Barr W, Cotterill L, Hoskins A. Improving community mental health nurse targeting of people with severe and enduring mental illness: experiences from one English health district. Journal of Advanced Nursing. Apr. 2001;34(1):117-27. International. [pmid: 11430599].
49 Barsky AJ. A research agenda for outpatient consultation-liaison psychiatry. General Hospital Psychiatry. Nov. 1993;15(6):381-5. Not on target, other publication type. [pmid: 8112561].
50 Barsky AJ, Delamater BA, Orav JE. Panic disorder patients and their medical care. Psychosomatics. Jan–Feb. 1999;40(1):50-6. Not integrated care. [pmid: 9989121].
51 Barsky AJ, Wyshak G, Klerman GL, et al. The prevalence of hypochondriasis in medical outpatients. Social Psychiatry & Psychiatric Epidemiology. Mar. 1990;25(2):89-94. Not integrated care. [pmid: 2336583].
52 Bartels SJ, Horn S, Sharkey P, et al. Treatment of depression in older primary care patients in health maintenance organizations. International Journal of Psychiatry in Medicine. 1997;27(3):215-31. Not integrated care. [pmid: 9565725].
53 Bartle C. Developing a service for children with iron deficiency anaemia. Nursing Standard. Jan 17–23. 2007;21(19):44-9. Not mental health condition. [pmid: 17288317].
54 Bartolucci AA. Meta-analysis: some clinical and statistical contributions in several medical disciplines. Yonsei Medical Journal. Apr 30. 2007;48(2):157-63. Not integrated care. [pmid: 17461511].
55 Bashir K, Blizard B, Bosanquet A, et al. The evaluation of a mental health facilitator in general practice: effects on recognition, management, and outcome of mental illness. British Journal of General Practice. Aug. 2000;50(457):626-9. International. [pmid: 11042913].
56 Bauer MS, McBride L, Williford WO, et al. Collaborative care for bipolar disorder: Part II. Impact on clinical outcome, function, and costs. Psychiatric Services. Jul. 2006;57(7):937-45. Not primary care setting. [pmid: 16816277].
57 Bauer MS, McBride L, Williford WO, et al. Collaborative care for bipolar disorder: part I. Intervention and implementation in a randomized effectiveness trial.[see comment]. Psychiatric Services. Jul. 2006;57(7):927-36. Not primary care setting. [pmid: 16816276].
58 Bauer MS, Williford WO, Dawson EE, et al. Principles of effectiveness trials and their implementation in VA Cooperative Study #430: ‘Reducing the efficacy-effectiveness gap ititlebipolar disorder’. Journal of Affective Disorders. Dec. 2001;67(13):61-78. Not on target, other publication type. [pmid: 11869753].
59 Baxter K, Peters TJ, Somerset M, et al. Anxiety amongst women with mild dyskaryosis: costs of an educational intervention. Family Practice. Aug. 1999;16(4):353-9. International. [pmid: 10493704].
60 Becker PM, McVey LJ, Saltz CC, et al. Hospital-acquired complications in a randomized controlled clinical trial of a geriatric consultation team. JAMA. May 1. 1987;257(17):2313-7. Not primary care setting. [pmid: 3553627].
61 Becker T, Holloway F, McCrone P, et al. Evolving service interventions in Nunhead and Norwood. PRiSM Psychosis Study. 2. British Journal of Psychiatry. Nov. 1998;173:371-5. Not integrated care. [pmid: 9926052].
62 Beers MH, Fingold SF, Ouslander JG, et al. Characteristics and quality of prescribing by doctors practicing in nursing homes. Journal of the American Geriatrics Society. Aug. 1993;41(8):802-7. Not primary care setting. [pmid: 8340556].
63 Beinecke RH, Shepard DS, Leung M, et al. Evaluation of the Massachusetts Behavioral Health Program: Year 8. Administration & Policy in Mental Health. Nov. 2002;30(2):141-57. Not included study design. [pmid: 12680618].
64 Bellinger D, Sloman J, Leviton A, et al. Low-level lead exposure and children's cognitive function in the preschool years. [erratum appears in Pediatrics 1994 Feb;93(2):A28]. Pediatrics. Feb. 1991;87(2):219-27. Not mental health condition. [pmid: 1987535].
65 Bennett FC, Guralnick MJ, Richardson HB J, et al. Teaching developmental pediatrics to pediatric residents: effectiveness of a structured curriculum. Pediatrics. Oct. 1984;74(4):514-22. Not integrated care. [pmid: 6207481].
66 Berber MJ. Pharmacological treatment of depression. Consulting with Dr Oscar. Canadian Family Physician. Nov. 1999;45:2663-8. Not integrated care. [pmid: 10587774].
67 Berger JL. Incorporation of the Tidal Model into the interdisciplinary plan of care—a program quality improvement project. Journal of Psychiatric & Mental Health Nursing. Aug. 2006;13(4):464-7. Not primary care setting. [pmid: 16867134].
68 Bergus GR, Hartz AJ, Noyes R J, et al. The limited effect of screening for depressive symptoms with the PHQ-9 in rural family practices. Journal of Rural Health. 2005;21(4):303-9. Not on target, other publication type. [pmid: 16294652].
69 Bernstein E, Bernstein J, Levenson S. Project ASSERT: an ED-based intervention to increase access to primary care, preventive services, and the substance abuse treatment system. Annals of Emergency Medicine. Aug. 1997;30(2):181-9. Not primary care setting. [pmid: 9250643].
70 Bhagwanjee A, Parekh A, Paruk Z, et al. Prevalence of minor psychiatric disorders in an adult African rural community in South Africa. Psychological Medicine. Sep. 1998;28(5):1137-47. Not primary care setting. [pmid: 9794021].
71 Bijl D, van Marwijk H, Beekman A, et al. A randomized controlled trial to improve the recognition, diagnosis and treatment of major depression in elderly people in general practice: Dtitle, first results and feasibility of the West Friesland. Study Primary Care Psychiatry. Aug. 2003;8(4):135-40. International.
72 Bijl D, van Marwijk HW, de Haan M, et al. Effectiveness of disease management programmes for recognition, diagnosis and treatment of depression in primary care. European Journal of General Practice. Mar. 2004;10(1):6-12. International. [pmid: 15060475].
73 Bilsker D, Goldner EM, Jones W. Health service patterns indicate potential benefit of supported self-management for depression in primary care.[see comment]. Canadian Journal of Psychiatry - Revue Canadienne de Psychiatrie. Feb. 2007;52(2):86-95. Not integrated care. [pmid: 17375863].
74 Bindman J, Johnson S, Wright S, et al. Integration between primary and secondary services in the care of the severely mentally ill: patients' and general practitioners' views.[see comment]. British Journal of Psychiatry. Aug. 1997;171:169-74. International. [pmid: 9337955].
75 Blanchard CG, Ruckdeschel JC. Psychosocial aspects of cancer in adults: implications for teaching medical students. Journal of Cancer Education. 1986;1(4):237-48. Not integrated care. [pmid: 3079146].
76 Bland RC, Newman SC, Orn H. Help-seeking for psychiatric disorders.[see comment]. Canadian Journal of Psychiatry - Revue Canadienne de Psychiatrie. Nov. 1997;42(9):935-42. Not integrated care. [pmid: 9429063].
77 Blankenstein AH, van der Horst HE, Schilte AF, et al. Development and feasibility of a modified reattribution model for somatising patients, applied by their own general practitioners. Patient Education & Counseling. Jul. 2002;47(3):229-35. International. [pmid: 12088601].
78 Bodlund O, Andersson SO, Mallon L. Effects of consulting psychiatrist in primary care. 1-year follow-up of diagnosing and treating anxiety and depression. Scandinavian Journal of Primary Health Care. Sep. 1999;17(3):153-7. International. [pmid: 10555244].
79 Bogner HR, Ford DE, Gallo JJ. The role of cardiovascular disease in the identification and management of depression by primary care physicians. American Journal of Geriatric Psychiatry. Jan. 2006;14(1):71-8. Not integrated care. [pmid: 16407584].
80 Boot D, Gillies P, Fenelon J, et al. Evaluation of the short-term impact of counseling in general practice. Patient Education & Counseling. Aug. 1994;24(1):79-89. International. [pmid: 7862598].
81 Borson S, Scanlan J, Hummel J, et al. Implementing routine cognitive screening of older adults in primary care: process and impact on physician behavior.[erratum appears in J Gen Intern Med. 2007 Aug;22(8):1224]. Journal of General Internal Medicine. Jun. 2007;22(6):811-7. Not mental health condition. [pmid: 17447100].
82 Borus JF. Neighborhood health centers as providers of primary mental-health care. New England Journal of Medicine. Jul 15. 1976;295(3):140-5. Not on target, other publication type. [pmid: 1272331].
83 Boskovich SJ. New concepts in nursing management of the TB patient: a community training program. Journal of Community Health Nursing. 1994;11(1):45-9. Not mental health condition. [pmid: 8201368].
84 Bosmans J, de Bruijne M, van Hout H, et al. Cost-effectiveness of a disease management program for major depression in elderly primary care patients.[see comment]. Journal of General Internal Medicine. Oct. 2006;21(10):1020-6. International. [pmid: 16836625].
85 Botoman VA. Noncardiac chest pain.[see comment]. Journal of Clinical Gastroenterology. Jan. 2002;34(1):6-14. Not mental health condition. [pmid: 11743240].
86 Bower P, Jerrim S, Gask L. Primary care mental health workers: role expectations, conflict and ambiguity. Health & Social Care in the Community. Jul. 2004;12(4):336-45. International. [pmid: 15272889].
87 Brach C, Falik M, Law C, et al. Mental health services: critical component of integrated primary care and substance abuse treatment. Journal of Health Care for the Poor & Underserved. 1995;6(3):322-41. Not on target, other publication type. [pmid: 7548490].
88 Bradley KA. Integrated outpatient treatment increased abstinence in men with alcohol-related illness who were ongoing drinkers. ACP Journal Club. Mar–Apr. 2000;132(2):67. International.
89 Brand CA, Jones CT, Lowe AJ, et al. A transitional care service for elderly chronic disease patients at risk of readmission. Australian Health Review. Dec 13. 2004;28(3):275-84. Not primary care setting. [pmid: 15595909].
90 Brands B, Blake J, Marsh D. Impact of methadone program philosophy changes on early treatment outcomes. Journal of Addictive Diseases. 2003;22(3):19-38. Not mental health condition. [pmid: 14621342].
91 Brekke JS, Ansel M, Long J, et al. Intensity and continuity of services and functional outcomes in the rehabilitation of persons with schizophrenia. Psychiatric Services. Feb. 1999;50(2):248-56. Not integrated care. [pmid: 10030485].
92 Bridgemohan CF, Levy S, Veluz AK, et al. Teaching paediatric residents about learning disorders: use of standardised case discussion versus multimedia computer tutorial.[see comment]. Medical Education. Aug. 2005;39(8):797-806. Not mental health condition. [pmid: 16048622].
93 Bridges K, Goldberg D, Evans B, et al. Determinants of somatization in primary care. Psychological Medicine. May. 1991;21(2):473-83. Not integrated care. [pmid: 1876652].
94 Briggs-Gowan MJ, Horwitz SM, Schwab-Stone ME, et al. Mental health in pediatric settings: distribution of disorders and factors related to service use. Journal of the American Academy of Child & Adolescent Psychiatry. Jul. 2000;39(7):841-9. Not integrated care. [pmid: 10892225].
95 Brindis C, Pfeffer R, Wolfe A. A case management program for chemically dependent clients with multiple needs. Journal of Case Management. 1995;4(1):22-8. Not on target, other publication type. [pmid: 7795539].
96 Briscoe M, Wilkinson G. General practitioners' use of community psychiatric nursing services: a preliminary survey. Journal of the Royal College of General Practitioners. Oct. 1989;39(327):412-4. Not integrated care. [pmid: 2560021].
97 Brodaty H, Draper BM, Millar J, et al. Randomized controlled trial of different models of care for nursing home residents with dementia complicated by depression or psychosis. Journal of Clinical Psychiatry. Jan. 2003;64(1):63-72. Not primary care setting. [pmid: 12590626].
98 Brook O, van Hout H, Nieuwenhuyse H, et al. Impact of coaching by community pharmacists on drug attitude of depressive primary care patients and acceptability to patients; a rtitlecontrolled trial. European Neuropsychopharmacology. Jan. 2003;13(1):1-9. Not integrated care. [pmid: 12480116].
99 Brown G, Bruce K. A nurse-led ADHD service for children and adolescents. Nursing Times. Oct 5–11. 2004;100(40):36-8. Not primary care setting. [pmid: 15526569].
100 Brown JB, Lent B, Stirling A, et al. Caring for seriously mentally ill patients. Qualitative study of family physicians' experiences. Canadian Family Physician. May. 2002;48:915-20. International. [pmid: 12053636].
101 Brown RF, Butow PN, Dunn SM, et al. Promoting patient participation and shortening cancer consultations: a randomised trial. British Journal of Cancer. Nov 2. 2001;85(9):1273-9. Not integrated care. [pmid: 11720460].
102 Brown RL, Leonard T, Saunders LA, et al. A two-item screening test for alcohol and other drug problems.[see comment]. Journal of Family Practice. Feb. 1997;44(2):151-60. Not integrated care. [pmid: 9040518].
103 Bruce DG, Paley GA, Underwood PJ, et al. Communication problems between dementia carers and general practitioners: effect on access to community support services. Medical Journal of Australia. Aug 19. 2002;177(4):186-8. Not integrated care. [pmid: 12175321].
104 Brudenell I. Parenting an infant during alcohol recovery. Journal of Pediatric Nursing. Apr. 2000;15(2):82-8. Not integrated care. [pmid: 10808623].
105 Bryant G, Rogers J. An evaluation of home and residential alcohol detoxification (including the client experience). Journal of Clinical Governance. 2001;9(4):181-5. Not primary care setting.
106 Brymer C, Cavanagh P, Denomy E, et al. The effect of a geriatric education program on emergency nurses. Journal of Emergency Nursing. Feb. 2001;27(1):27-32. Not primary care setting. [pmid: 11174267].
107 Bucknall AB, Robertson JR, Strachan JG. Use of psychiatric drug treatment services by heroin users from general practice. British Medical Journal Clinical Research Ed. Apr 12. 1986;292(6526):997-9. Not integrated care. [pmid: 3083985].
108 Buist-Bouwman MA. Collaborative care management improves physical functioning in older people with depression. Evidence-Based Mental Health. Nov. 2005;8(4):106. International. [pmid: 16246882].
109 Burbach FR, Harding S. GP referral letters to a community mental health team: an analysis of the quality and quantity of information. International Journal of Health Care Quality Assurance Incorporating Leadership in Health Services. 1997;10(23):67-72. International. [pmid: 10169236].
110 Burns LE. The epidemiology of fears and phobias in general practice. Journal of International Medical Research. 1980;8(Suppl 3):1-7. Not integrated care. [pmid: 7202813].
111 Burns T, Kendrick T. Care of long-term mentally ill patients by British general practitioners. Psychiatric Services. Dec. 1997;48(12):1586-8. International. [pmid: 9406270].
112 Buszewicz M, Pistrang N, Barker C, et al. Patients' experiences of GP consultations for psychological problems: a qualitative study. British Journal of General Practice. Jul. 2006;56(528):496-503. Not integrated care. [pmid: 16834875].
113 Butow P, Devine R, Boyer M, et al. Cancer consultation preparation package: changing patients but not physicians is not enough. Journal of Clinical Oncology. Nov 1. 2004;22(21):4401-9. Not mental health condition. [pmid: 15514382].
114 Byng R, Jones R, Leese M, et al. Exploratory cluster randomised controlled trial of shared care development for long-term mental illness.[erratum appears in Br J Gen Pract. 2004 Dec;54(509):948]. British Journal of General Practice. Apr. 2004;54(501):259-66. International. [pmid: 15113492].
115 Byng R, Norman I, Redfern S. Using Realistic Evaluation to Evaluate a Practice-level Intervention to Improve Primary Healthcare for Patients with Long-term Mental Illness. Evaluation: The International Journal of Theory, Research and Practice. Jan. 2005;11(1):69-93. Not on target, other publication type.
116 Byrne N, Regan C, Livingston G. Adherence to treatment in mood disorders. Current Opinion in Psychiatry. Jan. 2006;19(1):44-9. Not on target, other publication type. [pmid: 16612178].
117 Bystritsky A, Wagner AW, Russo JE, et al. Assessment of beliefs about psychotropic medication and psychotherapy: development of a measure for patients with anxiety disorders. General Hospital. Sep–Oct. 2005;27(5):313-8. Not on target, other publication type.
118 Cadoret RJ, Widmer RB, Troughton EP. Somatic complaints — harbinger of depression in primary care. Journal of Affective Disorders. Mar. 1980;2(1):61-70. Not integrated care. [pmid: 6448881].
119 Cahill S. Educational workshops and decision support software increase detection of dementia in the elderly in primary care settings. Evidence-Based Mental Health. Nov. 2006;9(4):102. International. [pmid: 17065299].
120 Caley LM, Shipkey N, Winkelman T, et al. Evidence-based review of nursing interventions to prevent secondary disabilities in fetal alcohol spectrum disorder. Pediatric Nursing. Mar–A. 2006;32(2):155-62. Not integrated care. [pmid: 16719426].
121 Callahan CM, Hendrie HC, Dittus RS, et al. Improving treatment of late life depression in primary care: a randomized clinical trial. Journal of the American Geriatrics Society. Aug. 1994;42(8):839-46. Not integrated care. [pmid: 8046193].
122 Calsyn DA, Saxon AJ, Bush KR, et al. The Addiction Severity Index medical and psychiatric composite scores measure similar domains as the SF-36 in substance-dependent veterans: concurrent and discriminant validity. Drug & Alcohol Dependence. Nov 11. 2004;76(2):165-71. Not integrated care. [pmid: 15488340].
123 Caltagirone C, Bianchetti A, Di Luca M, et al. Guidelines for the treatment of Alzheimer's disease from the Italian. Association of Psychogeriatrics Drugs & Aging. 2005;22(Suppl 1):1-26. Not mental health condition. [pmid: 16506439].
124 Camann MA. To your health: implementation of a wellness program for treatment staff and persons with mental illness. Archives of Psychiatric Nursing. Aug. 2001;15(4):182-7. Not primary care setting. [pmid: 11498811].
125 Campbell NC, Thain J, Deans HG, et al. Secondary prevention clinics for coronary heart disease: randomised trial of effect on health. BMJ. May 9. 1998;316(7142):1434-7. Not mental health condition. [pmid: 9572758].
126 Campion EW, Jette A, Berkman B. An interdisciplinary geriatric consultation service: a controlled trial. Journal of the American Geriatrics Society. Dec. 1983;31(12):792-6. Not primary care setting. [pmid: 6361104].
127 Camus V, Viret C, Porchet A, et al. Effect of changing referral mode to C-L Psychiatry for noncognitively impaired medical inpatients with emotional disorders. Journal of Psychosomatic Research. Jun. 2003;54(6):579-85. International. [pmid: 12781313].
128 Cape J, Harvey K, Johnson S, et al. Patients' views of the letters their psychiatrists and psychologists send to referrers. Journal of Mental Health. Aug. 2005;14(4):369-82. Not integrated care.
129 Carbone LA, Barsky AJ, Orav EJ, et al. Psychiatric symptoms and medical utilization in primary care patients. Psychosomatics. Nov–Dec. 2000;41(6):512-8. Not integrated care. [pmid: 11110115].
130 Carr VJ, Faehrmann C, Lewin TJ, et al. Determining the effect that consultation-liaison psychiatry in primary care has on family physicians' psychiatric knowledge and practice. Psychosomatic. May–Jun. 1997;38(3):217-29. International.
131 Carr VJ, Lewin TJ, Reid AL, et al. An evaluation of the effectiveness of a consultation-liaison psychiatry service in general practice.[see comment]. Australian & New Zealand Journal of Psychiatry. Oct. 1997;31(5):714-25. discussion 26–7. International. [pmid: 9400878].
132 Carr VJ, Lewin TJ, Walton JM, et al. Consultation-liaison psychiatry in general practice.[see comment]. Australian & New Zealand Journal of Psychiatry. Feb. 1997;31(1):85-94. International. [pmid: 9088491].
133 Chafetz L, Collins-Bride GM, White M. A nursing faculty practice for the severely mentally ill: merging practice with research. Nursing Outlook. Jul–Aug. 2004;52(4):209-14. Not on target, other publication type. [pmid: 15328509].
134 Charbonneau A, Rosen AK, Ash AS, et al. Measuring the quality of depression care in a large integrated health system. Medical Care. May. 2003;41(5):669-80. not integrated care. [pmid: 12719691].
135 Charlson ME, Cohen RP, Sears CL. General medicine consultation. Lessons from a clinical service. American Journal of Medicine. Jul. 1983;75(1):121-8. Medical education. [pmid: 6859076].
136 Charrois TL, Sadler C, Vohra S, et al. Complementary, holistic, and integrative medicine: St. John's wort. Pediatrics in Review. Feb. 2007;28(2):69-72. not mental health condition. [pmid: 17272523].
137 Chaudron LH, Caine ED. Suicide among women: a critical review. Journal of the American Medical Womens Association. 2004;59(2):125-34. Not integrated care.
138 Chaudron LH, Szilagyi PG, Kitzman HJ, et al. Detection of postpartum depressive symptoms by screening at well-child visits. Pediatrics. Mar. 2004;113(3 Pt 1):551-8. Not integrated care. [pmid: 14993549].
139 Chelminski PR, Ives TJ, Felix KM, et al. A primary care, multi-disciplinary disease management program for opioid-treated patients with chronic non-cancer pain and a high burden otitlepsychiatric comorbidity. BMC Health Services Research. Jan 13. 2005;5(1):3. Not mental health condition. [pmid: 15649331].
140 Chen TM, Huang FY, Chang C, et al. Using the PHQ-9 for depression screening and treatment monitoring for Chinese Americans in primary care. Psychiatric Services. Jul. 2006;57(7):976-81. Not on target, other publication type. [pmid: 16816282].
141 Chew-Graham C, Slade M, Montana C, et al. A qualitative study of referral to community mental health teams in the UK: exploring the rhetoric and the reality. BMC Health Services Research. 2007;7:117. International. [pmid: 17651489].
142 Chew-Graham CA, Lovell K, Roberts C, et al. A randomised controlled trial to test the feasibility of a collaborative care model for the management of depression in older people. British Journal of General Practice. May. 2007;57(538):364-70. International. [pmid: 17504586].
143 Chin MH, Su AW, Jin L, et al. Variations in the care of elderly persons with diabetes among endocrinologists, general internists, and geriatricians. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. Oct. 2000;55(10):M601-6. Not mental health condition.
144 Chisholm D, Sekar K, Kumar KK, et al. Integration of mental health care into primary care. Demonstration cost-outcome study in India and Pakistan. British Journal of Psychiatry. Jun. 2000;176:581-8. International. [pmid: 10974966].
145 Choi J. Development and evaluation of a computer-interpretable guideline for depression screening and initial management in primary care Choi, Jeeyae: Columbia U, US; 2006. Not on target, other publication type
146 Christensen H, Low LF, Anstey KJ. Prevalence, risk factors and treatment for substance abuse in older adults. Current Opinion in Psychiatry. Nov. 2006;19(6):587-92. Not integrated care. [pmid: 17012936].
147 Ciechanowski P, Wagner E, Schmaling K, et al. Community-integrated home-based depression treatment in older adults: a randomized controlled trial. JAMA: Journal of the American Medical Association. Apr 7. 2004;291(13):1569-77. Not primary care setting. [pmid: 15069044].
148 Cinar DN. The advantages and disadvantages of pacifier use. Contemporary Nurse. Jul–Aug. 2004;17(12):109-12. Not mental health condition. [pmid: 17929742].
149 Claassen CA, Trivedi MH, Rush AJ, et al. Clinical differences among depressed patients with and without a history of suicide attempts: findings from the STAR*D trial. Journal of Affective Disorders. Jan. 2007;97(13):77-84. Not integrated care. [pmid: 16824617].
150 Clark DF. The clinical psychologist in primary care. Social Science & Medicine - Medical Psychology & Medical Sociology. Nov. 1979;13A(6):707-13. International. [pmid: 538484].
151 Clarke DM, McKenzie DP, Smith GC. The recognition of depression in patients referred to a consultation-liaison service. Journal of Psychosomatic Research. Apr. 1995;39(3):327-34. International. [pmid: 7636776].
152 Cocksedge S, May C. Pastoral relationships and holding work in primary care: affect, subjectivity and chronicity. Chronic Illness. Jun. 2005;1(2):157-63. Not integrated care. [pmid: 17136921].
153 Coddington RD, King TL. Automated history taking in child psychiatry. American Journal of Psychiatry. Sep. 1972;129(3):276-82. Not integrated care. [pmid: 4559782].
154 Coe C, Spencer N, Barlow J, et al. Services for pre-school children with behaviour problems in a Midlands city. Child: Care, Health & Development. Nov. 2003;29(6):417-24. Not integrated care.
155 Cohen-Cole SA, Boker J, Bird J, et al. Psychiatric education improves internists' knowledge: a three-year randomized, controlled evaluation. Psychosomatic Medicine. Mar–Apr. 1993;55(2):212-8. Medical education. [pmid: 8475236].
156 Cole MG, McCusker J, Bellavance F, et al. Systematic detection and multidisciplinary care of delirium in older medical inpatients: a randomized trial.[see comment]. CMAJ Canadian Medical Association Journal. Oct 1. 2002;167(7):753-9. Not primary care setting. [pmid: 12389836].
157 Collins JW. Proposed criteria for referring diabetic retinopathy. Nurse Practitioner. 1988;13(4):21-2. Not primary care setting. [pmid: 3283610].
158 Conn DK. Collaborative care depression management for older adults: level of comorbidity does not affect outcome. Evidence-Based Mental Health. Nov. 2005;8(4):105. International. [pmid: 16246881].
159 Conradi HJ, de Jonge P, Kluiter H, et al. Enhanced treatment for depression in primary care: long-term outcomes of a psycho-educational prevention program alone and enriched wtitlepsychiatric consultation or cognitive behavioral therapy. Psychological Medicine. Jun. 2007;37(6):849-62. International. [pmid: 17376257].
160 Conway J, Graycar A, Whimp JR. General practice and professional coordination. Medical Journal of Australia. May 1. 1976;1(18):666-9. International. [pmid: 950941].
161 Cook S, Howe A, Veal J. A different ball game altogether: staff views on a primary mental healthcare service. Primary Care Mental Health. 2004;2(2):77-89. International.
162 Cooperman NA, Parsons JT, Chabon B, et al. The development and feasibility of an intervention to improve HAART adherence among HIV-positive patients receiving primary care in methadone clinics. Journal of HIV/AIDS and Social Services. 2007;6(12):101-20. Not mental health condition.
163 Cornel M, Knibbe RA, Drop MJ, et al. The medical profile of unidentified problem drinkers in general practice: test of an hypothesis. Alcohol & Alcoholism. Sep. 1995;30(5):651-9. Not integrated care. [pmid: 8554650].
164 Corney RH. The effectiveness of attached social workers in the management of depressed female patients in general practice. Psychological Medicine - Monograph Supplement. 1984;6:1-47. International. [pmid: 6387754].
165 Cornford CS, Hill A, Reilly J. How patients with depressive symptoms view their condition: A qualitative study. Family Practice. Aug. 2007;24(4):358-64. Not integrated care. [pmid: 17630269].
166 Cornuz J. Treating tobacco use and dependence in clinical practice. Expert Opinion on Pharmacotherapy. Apr. 2006;7(6):783-92. Not mental health condition. [pmid: 16556092].
167 Couch C, Sheffield P, Gerthoffer T, et al. Clinical outcomes in patients with type 2 diabetes managed by a diabetes resource nurse in a primary care practice. Baylor University Medical Center Proceedings. Jul. 2003;16(3):336-40. Not mental health condition. [pmid: 16278705].
168 Coultas D, Frederick J, Barnett B, et al. A randomized trial of two types of nurse-assisted home care for patients with COPD. Chest. Oct. 2005;128(4):2017-24. Not primary care setting. [pmid: 16236850].
169 Coyne JC, Brown G, Datto C, et al. The benefits of a broader perspective in case-finding for disease management of depression: early lessons from the PROSPECT Study. International Journal of Geriatric Psychiatry. Jun. 2001;16(6):570-6. Not on target, other publication type. [pmid: 11424165].
170 Coyne JC, Koppel J, Colenda CC, et al. Interventions for treatment of depression in primary care. JAMA: Journal of the American Medical Association. Jun 16. 2004;291(23):2814-6. Not on target, other publication type. [pmid: 15199023].
171 Craven MA, Cohen M, Campbell D, et al. Mental health practices of Ontario family physicians: a study using qualitative methodology. Canadian Journal of Psychiatry - Revue Canadienne de Psychiatrie. Nov. 1997;42(9):943-9. Not integrated care. [pmid: 9429064].
172 Creed F, Marks B. Liaison psychiatry in general practice: a comparison of the liaison-attachment scheme and shifted outpatient clinic models. Journal of the Royal College of General Practitioners. Dec. 1989;39(329):514-7. International. [pmid: 2558209].
173 Crimlisk HL, Bhatia KP, Cope H, et al. Patterns of referral in patients with medically unexplained motor symptoms. Journal of Psychosomatic Research. Sep. 2000;49(3):217-9. Not integrated care. [pmid: 11110993].
174 Crosse C. A meaningful day: integrating psychosocial rehabilitation into community treatment of schizophrenia. Medical Journal of Australia. May 5. 2003;178(Suppl):S76-8. International. [pmid: 12720528].
175 Cullen W, Stanley J, Langton D, et al. Hepatitis C infection among injecting drug users in general practice: a cluster randomised controlled trial of clinical guidelines' implementation. British Journal of General Practice. Nov. 2006;56(532):848-56. Not mental health condition. [pmid: 17132352].
176 Cullivan R, Crown J, Walsh N. The use of psychotropic medication in patients referred to a psycho-oncology service. Psycho-Oncology. Jul–Aug. 1998;7(4):301-6. Not integrated care. [pmid: 9741069].
177 Curry DM, Duby JC. Identification and referral by nurses of children at risk Issues in Comprehensive. Pediatric Nursing. Jan–Mar. 1995;18(1):67-74. Not mental health condition.
178 Da Canhota CM, Piterman L. Depressive disorders in elderly Chinese patients in Macau: a comparison of general practitioners' consultations with a depression screening scale. Australian & New Zealand Journal of Psychiatry. Jun. 2001;35(3):336-44. Not integrated care. [pmid: 11437807].
179 Daaleman TP, Frey B. Prevalence and patterns of physician referral to clergy and pastoral care providers. Archives of Family Medicine. Nov–Dec. 1998;7(6):548-53. Not integrated care. [pmid: 9821829].
180 Damestoy N, Collin J, Lalande R. Prescribing psychotropic medication for elderly patients: some physicians' perspectives. CMAJ Canadian Medical Association Journal. Jul 27. 1999;161(2):143-5. Not integrated care. [pmid: 10439822].
181 Dancey A, Rayatt S, Courthold J, et al. Views of UK melanoma patients on routine follow-up care. British Journal of Plastic Surgery. Mar. 2005;58(2):245-50. Not mental health condition. [pmid: 15710122].
182 Danner CC, Robinson BBE, Striepe MI, et al. Running from the demon: Culturally specific group therapy for depressed Hmong women in a family medicine residency clinic. Women & Therapy. 2007;30(12):151-76. Not integrated care.
183 Darbishire L, Ridsdale L, Seed PT. Distinguishing patients with chronic fatigue from those with chronic fatigue syndrome: a diagnostic study in UK primary care. British Journal of General Practice. Jun. 2003;53(491):441-5. Not mental health condition. [pmid: 12939888].
184 Dawson NV, Dadheech G, Speroff T, et al. The effect of patient gender on the prevalence and recognition of alcoholism on a general medicine inpatient service. Journal of General Internal Medicine. Jan–Feb. 1992;7(1):38-45. Not primary care setting. [pmid: 1548546].
185 de Cruppe W, Hennch C, Buchholz C, et al. Communication between psychosomatic C-L consultants and general practitioners in a German health care system. General Hospital Psychiatry. Jan–Feb. 2005;27(1):63-72. International. [pmid: 15694220].
186 De Filippo E, Signorini A, Bracale R, et al. Hospital admission and mortality rates in anorexia nervosa: experience from an integrated medical-psychiatric outpatient treatment. Eating & Weight Disorders: EWD. Dec. 2000;5(4):211-6. International. [pmid: 11216129].
187 de Jonge P, Latour CH, Huyse FJ. Implementing psychiatric interventions on a medical ward: effects on patients' quality of life and length of hospital stay. Psychosomatic Medicine. Nov–Dec. 2003;65(6):997-1002. Not primary care setting. [pmid: 14645778].
188 de Martino M, Galli L, Guarino Amato A, et al. Human immunodeficiency virus type 1 infection, clinical trials and ethics in paediatrics. Acta Paediatrica Supplement. Jun. 1997;421:78-85. Not mental health condition. [pmid: 9240864].
189 de Oliveira SR, Abdo CH. The Sexuality Project (Pro-Sex) of the Institute of Psychiatry of the HCFMUSP: first year of activities. Sao Paulo Medical Journal = Revista Paulista de Medicina. Jul–Aug. 1996;114(4):1208-15. Not primary care setting. [pmid: 9197036].
190 Degenhardt L, Knox S, Barker B, et al. The management of alcohol, tobacco and illicit drug use problems by general practitioners in Australia. Drug & Alcohol Review. Nov. 2005;24(6):499-506. Not integrated care. [pmid: 16361206].
191 Del Toro IM, Larsen DA, Carter AP. A new approach to alcoholism detection in primary care. Journal of Mental Health Administration. 1994;21(2):124-35. Not on target, other publication type. [pmid: 10133774].
192 den Ouden DJ, Dirkzwager AJ, Yzermans CJ. Health problems presented in general practice by survivors before and after a fireworks disaster: associations with mental health care Scandinavian. Journal of Primary Health Care. Sep. 2005;23(3):137-41. Not integrated care.
193 Dennis DL, Steadman HJ, Cocozza JJ. The impact of federal systems integration initiatives on services for mentally ill homeless persons. Mental Health Services Research. Sep. 2000;2(3):165-74. Not on target, other publication type. [pmid: 11256725].
194 Desai RA, Stefanovics EA, Rosenheck RA. The role of psychiatric diagnosis in satisfaction with primary care: data from the department of veterans affairs. Medical Care. Dec. 2005;43(12):1208-16. Not integrated care. [pmid: 16299432].
195 Dew K, Dowell A, McLeod D, et al. “The glorious twilight zone of uncertainty”: mental health consultations in general practice in New Zealand. Social Science & Medicine. Sep. 2005;61(6):1189-200. International. [pmid: 15970230].
196 DeWilde S, Carey IM, Richards N, et al. Do children who become autistic consult more often after MMR vaccination?. British Journal of General Practice. Mar. 2001;51(464):226-7. Not integrated care. [pmid: 11255906].
197 Dey P, Roaf E, Collins S, et al. Randomized controlled trial to assess the effectiveness of a primary health care liaison worker in promoting shared care for opiate users. Journal of Public Health Medicine. Mar. 2002;24(1):38-42. Not mental health condition. [pmid: 11939381].
198 Didham R, Dovey S, Reith D. Characteristics of general practitioner consultations prior to suicide: a nested case-control study in New Zealand. New Zealand Medical Journal. 2006;119(1247):U2358. Not integrated care. [pmid: 17195851].
199 Dilling H, Weyerer S, Fichter M. The upper Bavarian studies. Acta Psychiatrica Scandinavica, Supplementum. 1989;348:113-39. discussion 67–78. International. [pmid: 2801175].
200 Dilts SL J, Mann N, Dilts JG. Accuracy of referring psychiatric diagnosis on a consultation-liaison service. Psychosomatics. Sep–Oct. 2003;44(5):407-11. Not on target, other publication type. [pmid: 12954915].
201 Djuricich AM. Teaching medical residents about teenagers: an introductory curriculum in adolescent medicine. Academic Medicine. Jul. 2002;77(7):745-6. Not integrated care. [pmid: 12114165].
202 Dobscha SK, Ganzini L. A program for teaching psychiatric residents to provide integrated psychiatric and primary medical care. Psychiatric Services. Dec. 2001;52(12):1651-3. Medical education. [pmid: 11726758].
203 Dolbeault S, Szporn A, Holland JC. Psycho-oncology: where have we been? Where are we going?. European Journal of Cancer. Oct. 1999;35(11):1554-8. Not primary care setting. [pmid: 10673961].
204 Doolittle GC. Telemedicine in Kansas: the successes and the challenges. Journal of Telemedicine & Telecare. 2001;7(Suppl 2):43-6. Not on target, other publication type. [pmid: 11747656].
205 Douglas SL, Daly BJ, Kelley CG, et al. Impact of a disease management program upon caregivers of chronically critically ill patients.[erratum appears in Chest. 2006 Mar;129(3):831]. Chest. Dec. 2005;128(6):3925-36. Not mental health condition. [pmid: 16354865].
206 Dowling S, Hubert J, White S, et al. Bereaved adults with intellectual disabilities: a combined randomized controlled trial and qualitative study of two community-based interventions. Journal of Intellectual Disability Research. Apr. 2006;50(Pt 4):277-87. Not mental health condition. [pmid: 16507032].
207 Dowsett SM, Saul JL, Butow PN, et al. Communication styles in the cancer consultation: preferences for a patient-centred approach. Psycho-Oncology. Mar–Apr. 2000;9(2):147-56. Not mental health condition. [pmid: 10767752].
208 Drew L, Delacy F. Improving the general health of persons with psychosis. Australasian Psychiatry. Aug. 2007;15(4):320-3. International. [pmid: 17612886].
209 Drummond DC. Alcohol interventions: do the best things come in small packages?. Addiction. Apr. 1997;92(4):375-9. Not on target, other publication type. [pmid: 9177059].
210 Duaso MJ, Cheung P. Health promotion and lifestyle advice in a general practice: what do patients think?[see comment]. Journal of Advanced Nursing. Sep. 2002;39(5):472-9. Not integrated care. [pmid: 12175356].
211 Dubowitz H, Black M, Harrington D. The diagnosis of child sexual abuse.[see comment]. American Journal of Diseases of Children. Jun. 1992;146(6):688-93. Not integrated care. [pmid: 1595624].
212 Duggan CM, Mitchell G, Nikles CJ, et al. Managing ADHD in general practice. N of 1 trials can help!. Australian Family Physician. Dec. 2000;29(12):1205-9. International. [pmid: 11140235].
213 Dunn SF, Gilchrist VJ. Sexual assault Primary Care; Clinics in Office. Practice. Jun. 1993;20(2):359-73. Not mental health condition.
214 Dunsis A, Smith GC. Consultation-liaison psychiatry in an obstetric service.[see comment]. Australian & New Zealand Journal of Psychiatry. Feb. 1996;30(1):63-73. Not primary care setting. [pmid: 8724328].
215 Durance PW, Gibson TB, Davis-Sacks ML, et al. Multifacility utilization by the chronically mentally ill in the Department of Veterans Affairs. Journal of Mental Health Administration. 1992;19(2):178-94. Not on target, other publication type. [pmid: 10121510].
216 Durand MA, King M. Specialist treatment versus self-help for bulimia nervosa: a randomised controlled trial in general practice. British Journal of General Practice. May. 2003;53(490):371-7. International. [pmid: 12830564].
217 Dyer CB, Pavlik VN, Murphy KP, et al. The high prevalence of depression and dementia in elder abuse or neglect. Journal of the American Geriatrics Society. Feb. 2000;48(2):205-8. Not integrated care. [pmid: 10682951].
218 Dyer JG, Hammill K, Regan-Kubinski MJ, et al. The psychiatric-primary care nurse practitioner: a futuristic model for advanced practice psychiatric-mental health nursing.[see comment]. Archives of Psychiatric Nursing. Feb. 1997;11(1):2-12. Medical education. [pmid: 9046638].
219 Eagles JM, Howie FL, Cameron IM, et al. Use of health care services in seasonal affective disorder.[see comment]. British Journal of Psychiatry. May. 2002;180:449-54. Not integrated care. [pmid: 11983643].
220 Eagles JM, Naji SA, Gray DA, et al. Seasonal affective disorder among primary care consulters in January: prevalence and month by month consultation patterns. Journal of Affective Disorders. Apr. 1998;49(1):1-8. Not integrated care. [pmid: 9574854].
221 Eastman C, McPherson I. As others see us: general practitioners' perceptions of psychological problems and the relevance of clinical psychology. British Journal of Clinical Psychology. Jun. 1982;21(Pt 2):85-92. Not integrated care. [pmid: 7126957].
222 Eastwood MR. Screening for psychiatric disorder. Psychological Medicine. May. 1971;1(3):197-208. International. [pmid: 5148528].
223 Ecob R, Croudace TJ, White IR, et al. Multilevel investigation of variation in HoNOS ratings by mental health professionals: a naturalistic study of consecutive referrals. International Journal of Methods in Psychiatric Research. 2004;13(3):152-64. Not integrated care. [pmid: 15297899].
224 Edge D. Perinatal depression: its absence among Black Caribbean women British Journal of Midwifery 2006 Nov; 14(11):646–50, 52. Not integrated care
225 Edwards MA, Patel AC. Telemedicine in the state of Maine: a model for growth driven by rural needs Telemedicine. Journal & E-Health. 2003;9(1):25-39. Not included study design.
226 Ehrmann Feldman D, Couture M, Grilli L, et al. When and by whom is concern first expressed for children with neuromotor problems?[see comment]. Archives of Pediatrics & Adolescent Medicine. Sep. 2005;159(9):882-6. [pmid: 16143749].
227 Eisen P. Potential for psychiatric leadership in health care. Australian & New Zealand Journal of Psychiatry. Jun. 1986;20(2):107-11. Not mental health condition. [pmid: 3464260].
228 el-Guebaly N, Hodgins DC, Armstrong S, et al. Methodological and clinical challenges in evaluating treatment outcome of substance-related disorders and comorbidity. Canadian Journal of Psychiatry - Revue Canadienne de Psychiatrie. Apr. 1999;44(3):264-70. Not integrated care. [pmid: 10225128].
229 Elhai JD, Don Richardson J, Pedlar DJ. Predictors of general medical and psychological treatment use among a national sample of peacekeeping veterans with health problems. Journal of Anxiety Disorders. 2007;21(4):580-9. Not integrated care. [pmid: 16965892].
230 Elhai JD, Ford JD. Correlates of mental health service use intensity in the National Comorbidity Survey and National Comorbidity Survey Replication. Psychiatric Services. Aug. 2007;58(8):1108-15. Not included study design. [pmid: 17664523].
231 Elkins TE, Gafford LS, Wilks CS, et al. A model clinic approach to the reproductive health concerns of the mentally handicapped. Obstetrics & Gynecology. Aug. 1986;68(2):185-8. Not mental health condition. [pmid: 3737034].
232 Ell K, Quon B, Quinn DI, et al. Improving treatment of depression among low-income patients with cancer: The design of the ADAPt-C study. General Hospital Psychiatry. May–Jun. 2007;29(3):223-31. Not primary care setting. [pmid: 17484939].
233 Ell K, Sanchez K, Vourlekis B, et al. Depression, correlates of depression, and receipt of depression care among low-income women with breast or gynecologic cancer. Journal of Clinical Oncology. May 1. 2005;23(13):3052-60. Not integrated care. [pmid: 15860863].
234 Ellila H, Valimaki M, Warne T, et al. Ideology of nursing care in child psychiatric inpatient treatment. Nursing Ethics: an International Journal for Health Care Professionals. Sep. 2007;14(5):583-96. Not primary care setting.
235 Ellsbury K, Montano D, Krafft K. A survey of the attitudes of physician specialists toward capitation-based health plans with primary care gatekeepers. Qrb Quality Review Bulletin. Aug. 1990;16(8):294-300. Not integrated care. [pmid: 2122355].
236 Emmanuel JS, McGee A, Ukoumunne OC, et al. A randomised controlled trial of enhanced key-worker liaison psychiatry in general practice. Social Psychiatry & Psychiatric Epidemiology. Jun. 2002;37(6):261-6. International. [pmid: 12111030].
237 Enguidanos SM, Davis C, Katz L. Shifting the paradigm in geriatric care management: moving from the medical model to patient-centered care. Social Work in Health Care. 2005;41(1):1-16. Not on target, other publication type. [pmid: 16048853].
238 Epps RP, Manley MW. Prevention of tobacco use during childhood and adolescence. Five steps to prevent the onset of smoking. Cancer. Aug 1. 1993;72(3 Suppl):1002-4. Not mental health condition. [pmid: 8334651].
239 Escobar JI, Gara MA, Diaz-Martinez AM, et al. Effectiveness of a time-limited cognitive behavior therapy type intervention among primary care patients with medically unexplained symptoms. Annals of Family Medicine. Jul–Aug. 2007;5(4):328-35. Not integrated care. [pmid: 17664499].
240 Evans BJ, Kiellerup FD, Stanley RO, et al. A communication skills programme for increasing patients' satisfaction with general practice consultations. British Journal of Medical Psychology. Dec. 1987;60(Pt 4):373-8. Not integrated care. [pmid: 3426975].
241 Evans KR. Ancillary services for individuals living with HIV/AIDS. Nursing Clinics of North America. Sep. 2006;41(3):383-93. Not mental health condition. [pmid: 16908231].
242 Evans ME, Huz S, McNulty T, et al. Child, family, and system outcomes of intensive case management in New York State. Psychiatric Quarterly. 1996;67(4):273-86. Not primary care setting. [pmid: 8938828].
243 Fairhurst K, Dowrick C. Problems with recruitment in a randomized controlled trial of counselling in general practice: causes and implications. Journal of Health Services & Research Policy. Apr. 1996;1(2):77-80. International.
244 Falanga V, Schachner LA, Rae V, et al. Dermatologic consultations in the hospital setting.[see comment]. Archives of Dermatology. Aug. 1994;130(8):1022-5. Not primary care setting. [pmid: 8053699].
245 Fallon WF J, Rader E, Zyzanski S, et al. Geriatric outcomes are improved by a geriatric trauma consultation service. Journal of Trauma-Injury Infection & Critical Care. Nov. 2006;61(5):1040-6. Not primary care setting.
246 Falloon IR, Kydd RR, Coverdale JH, et al. Early detection and intervention for initial episodes of schizophrenia. Schizophrenia Bulletin. 1996;22(2):271-82. Not primary care setting. [pmid: 8782286].
247 Fang H, Rizzo JA. Do psychiatrists have less access to medical services for their patients?. The Journal of Mental Health Policy & Economics. Jun. 2007;10(2):63-71. Not integrated care. [pmid: 17603147].
248 Farmer AE, Griffiths H. Labelling and illness in primary care: comparing factors influencing general practitioners' and psychiatrists' decisions regarding patient referral to mental illness services. Psychological Medicine. Aug. 1992;22(3):717-23. Not integrated care. [pmid: 1410095].
249 Farragher B, Walsh N. Joint care admissions to a psychiatric unit: a prospective analysis.[see comment]. General Hospital Psychiatry. Mar. 1998;20(2):73-7. Not primary care setting. [pmid: 9582589].
250 Feinman JA, Cardillo D, Palmer J, et al. Development of a model for the detection and treatment of depression in primary care. Psychiatric Quarterly. 2000;71(1):59-78. Not included study design. [pmid: 10736817].
251 Feinstein RE, Blumenfield M, Orlowski B, et al. A national survey of cardiovascular physicians' beliefs and clinical care practices when diagnosing and treating depression in patients with cardiovascular disease. Cardiology in Review. Jul–Aug. 2006;14(4):164-9. Not primary care setting. [pmid: 16788327].
252 Feldman HH. Canadian guidelines for the development of antidementia therapies: 2nd Canadian conference on antidementia drug guidelines: Introduction Canadian. Journal of Neurological Sciences. Mar. 2007;34(Suppl 1):S1-S2. Not mental health condition.
253 Fenta H, Hyman I, Noh S. Mental health service utilization by Ethiopian immigrants and refugees in Toronto. Journal of Nervous & Mental Disease. Dec. 2006;194(12):925-34. Not integrated care. [pmid: 17164631].
254 Fenton WS, Stover ES. Mood disorders: cardiovascular and diabetes comorbidity. Current Opinion in Psychiatry. Jul. 2006;19(4):421-7. Not on target, other publication type. [pmid: 16721175].
255 Fernandez J, Rooney G, Leahy M, et al. Shared care: a working relationship?. Nurse 2 Nurse. Aug. 2004;4(7):43-5. International.
256 Ferris LE, Permaul JA. Wife assault: an Ontario study of the referral routes of urban and rural family physicians. Journal of Women's Health. Fall. 1992;1(3):219-22. Not mental health condition.
257 Ferry JL, Abramson JS. Toward understanding the clinical aspects of geriatric case management. Social Work in Health Care. 2005;42(1):35-56. Not on target, other publication type. [pmid: 16236648].
258 Fickel JJ, Parker LE, Yano EM, et al. Primary care - mental health collaboration: an example of assessing usual practice and potential barriers. Journal of Interprofessional Care. Mar. 2007;21(2):207-16. Not on target, other publication type. [pmid: 17365393].
259 Field EA, Longman LP, Bucknall R, et al. The establishment of a xerostomia clinic: a prospective study. British Journal of Oral & Maxillofacial Surgery. Apr. 1997;35(2):96-103. Not mental health condition. [pmid: 9146866].
260 Fiellin DA, O'Connor PG, Chawarski M, et al. Processes of care during a randomized trial of office-based treatment of opioid dependence in primary care. American Journal on Addictions. 2004;13(Suppl 1):S67-78. Not mental health condition. [pmid: 15204676].
261 Fihn SD, McDonell MB, Diehr P, et al. Effects of sustained audit/feedback on self-reported health status of primary care patients. American Journal of Medicine. Feb 15. 2004;116(4):241-8. Not integrated care. [pmid: 14969652].
262 Finnegan A, Finnegan S. Assessing the effectiveness of the British Army's mental health service. British Journal of Nursing. Jun 28–Jul 11. 2007;16(12):725-30. Not integrated care. [pmid: 17851361].
263 Finney JW, Riley AW, Cataldo MF. Psychology in primary health care: effects of brief targeted therapy on children's medical care utilization. Journal of Pediatric Psychology. Aug. 1991;16(4):447-61. Not on target, other publication type. [pmid: 1941425].
264 Finney JW, Willenbring ML, Moos RH. Improving the quality of VA care for patients with substance-use disorders: the Quality Enhancement Research Initiative (QUERI) substance abuse module. Medical Care. Jun. 2000;38(6 Suppl 1):I105-13. Not mental health condition. [pmid: 10843275].
265 Finucane A, Mercer SW. An exploratory mixed methods study of the acceptability and effectiveness of Mindfulness-Based Cognitive Therapy for patients with active depression and anxiety in primary care. BMC Psychiatry. 2006;6:14. International. [pmid: 16603060].
266 Fitzpatrick NK, Shah S, Walker N, et al. The determinants and effect of shared care on patient outcomes and psychiatric admissions - an inner city primary care cohort study. Social Psychiatry & Psychiatric Epidemiology. Feb. 2004;39(2):154-63. International. [pmid: 15052398].
267 Fleming MF, Graham AW. Screening and brief interventions for alcohol use disorders in managed care settings. Recent Developments in Alcoholism. 2001;15:393-416. Not integrated care. [pmid: 11449755].
268 Fogel BS, Stoudemire A, Houpt JL. Contrasting models for combined medical and psychiatric inpatient treatment. American Journal of Psychiatry. Sep. 1985;142(9):1085-9. Not primary care setting. [pmid: 3927752].
269 Forchuk C, Chan L, Schofield R, et al. Bridging the discharge process. Canadian Nurse. Mar. 1998;94(3):22-6. Not primary care setting. [pmid: 9633317].
270 Ford R, Barnes A, Davies R, et al. Maintaining contact with people with severe mental illness: 5-year follow-up of assertive outreach. Social Psychiatry & Psychiatric Epidemiology. Sep. 2001;36(9):444-7. Not integrated care. [pmid: 11766976].
271 Foster A, Jordan K, Croft P. Is frequent attendance in primary care disease-specific?. Family Practice. Aug. 2006;23(4):444-52. Not integrated care. [pmid: 16675502].
272 Foster PW, Ritchie AW, Jones DJ. Prospective analysis of scrotal pathology referrals - are referrals appropriate and accurate?. Annals of the Royal College of Surgeons of England. Jul. 2006;88(4):363-6. Not mental health condition. [pmid: 16834856].
273 Fraguas R J, Henriques SG J, De Lucia MS, et al. The detection of depression in medical setting: a study with PRIME-MD.[erratum appears in J Affect Disord. 2006 Nov;96(1–2):139 Note: Gonsalves Henriques, Sergio Jr [corrected to Henriques, Sergio Gonsalves Jr]; Rossi Menezes, Paulo [corrected to Menezes, Paulo Rossi]; Farid Gattaz, Wagner [corrected to Gattaz, Wagner Farid]; Arruda Martins, Milton [corrected to Martins, Milton Arruda]]. Journal of Affective Disorders. Mar. 2006;91(1):11-7. Not integrated care. [pmid: 16427132].
274 France R, Robson M. Work of the clinical psychologist in general practice: preliminary communication. Journal of the Royal Society of Medicine. Mar. 1982;75(3):185-9. International. [pmid: 7069684].
275 Frank C. Dementia workup. Deciding on laboratory testing for the elderly.[see comment]. Canadian Family Physician. Jul. 1998;44:1489-95. Not mental health condition. [pmid: 9678278].
276 Frank SH. Expectations disease: a model for understanding stress, control and dependent behaviour. Family Practice. Mar. 1993;10(1):23-33. Not integrated care. [pmid: 8477889].
277 Franks P, Williams GC, Zwanziger J, et al. Why do physicians vary so widely in their referral rates?. Journal of General Internal Medicine. Mar. 2000;15(3):163-8. Not integrated care. [pmid: 10718896].
278 Freeman T, Peck E. Evaluating partnerships: a case study of integrated specialist mental health services. Health & Social Care in the Community. Sep. 2006;14(5):408-17. International. [pmid: 16918833].
279 Friedmann PD, Hendrickson JC, Gerstein DR, et al. Do mechanisms that link addiction treatment patients to primary care influence subsequent utilization of emergency and hospital care?. Medical Care. Jan. 2006;44(1):8-15. Not mental health condition. [pmid: 16365607].
280 Frischer M, Norwood J, Heatlie H, et al. A comparison of trends in problematic drug misuse from two reporting systems. Journal of Public Health Medicine. Sep. 2000;22(3):362-7. Not integrated care. [pmid: 11077911].
281 Fritzsche K, Larisch A, Cierpka M, et al. Improving the biopsychosocial competence of German primary care physicians in diagnosing and treating somatoform disorders Families. Systems & Health. Fall. 2004;22(3):352-64. Medical education.
282 Fritzsche K, Struss Y, Stein B, et al. Psychosomatic liaison service in hematological oncology: need for psychotherapeutic interventions and their realization. Hematological Oncology. Jun. 2003;21(2):83-9. Not primary care setting. [pmid: 12802813].
283 Frostholm L, Fink P, Oernboel E, et al. The uncertain consultation and patient satisfaction: the impact of patients' illness perceptions and a randomized controlled trial on the training of physicians' communication skills. Psychosomatic Medicine. Nov–Dec. 2005;67(6):897-905. International. [pmid: 16314594].
284 Fucito L, Gomes B, Murnion B, et al. General practitioners' diagnostic skills and referral practices in managing patients with drug and alcohol-related health problems: implications for medical training and education programmes. Drug & Alcohol Review. Dec. 2003;22(4):417-24. Not integrated care. [pmid: 14660131].
285 Fuller J, Kelly B, Sartore G, et al. Use of social network analysis to describe service links for farmers' mental health. Australian Journal of Rural Health. Apr. 2007;15(2):99-106. Not integrated care. [pmid: 17441818].
286 Gage JD, Everett KD, Bullock L. Integrative review of parenting in nursing research.[see comment]. Journal of Nursing Scholarship. 2006;38(1):56-62. Not mental health condition. [pmid: 16579325].
287 Gahagan S, Sharpe TT, Brimacombe M, et al. Pediatricians' knowledge, training, and experience in the care of children with fetal alcohol syndrome. Pediatrics. Sep. 2006;118(3):e657-68. Not integrated care. [pmid: 16950957].
288 Gaitatzis A, Carroll K, Majeed A, et al. The epidemiology of the comorbidity of epilepsy in the general population.[see comment]. Epilepsia. Dec. 2004;45(12):1613-22. Not mental health condition. [pmid: 15571520].
289 Galambos C, Rocha C, McCarter AK, et al. Managed care and mental health: personal realities. Journal of Health & Social Policy. 2004;20(1):1-22. Not on target, other publication type. [pmid: 15914376].
290 Garland EJ. Rages and refusals. Managing the many faces of adolescent anxiety. Canadian Family Physician. May. 2001;47:1023-30. Not integrated care. [pmid: 11398717].
291 Gask L, Ludman E, Schaefer J. Qualitative study of an intervention for depression among patients with diabetes: how can we optimize patient-professional interaction?. Chronic Illness. Sep. 2006;2(3):231-42. International. [pmid: 17007699].
292 Gater R, Goldberg D, Jackson G, et al. The care of patients with chronic schizophrenia: a comparison between two services. Psychological Medicine. Nov. 1997;27(6):1325-36. Not primary care setting. [pmid: 9403904].
293 Gavigan P, Carr A, McKeon P. Urban public attitudes to the treatment of psychological problems and depression in general practice Irish. Medical Journal. Oct. 2000;93(7):200-2. Not integrated care.
294 Gavin B, Cullen W, O'Donoghue B, et al. Schizophrenia in general practice: a national survey of general practitioners in Ireland. Irish Journal of Medical Science. Jul–Sep. 2005;174(3):38-42. Not integrated care. [pmid: 16285337].
295 Gelfand K, Geffken G, Lewin A, et al. An initial evaluation of the design of pediatric psychology consultation service with children with diabetes. Journal of Child Health Care. Jun. 2004;8(2):113-23. International. [pmid: 15157367].
296 Geller G, Tambor ES, Chase GA, et al. Incorporation of genetics in primary care practice. Will physicians do the counseling and will they be directive?[see comment]. Archives of Family Medicine. Nov. 1993;2(11):1119-25. Not integrated care. [pmid: 8124486].
297 Gensichen J. IMPACT collaborative care improves depression in elderly patients in primary care in the longer term. Evidence-Based Mental Health. Aug. 2006;9(3):76. International. [pmid: 16868195].
298 Gensichen J, Torge M, Peitz M, et al. Case management for the treatment of patients with major depression in general practices—rationale, design and conduct of a cluster randomized controlled trial—PRoMPT (PRimary care Monitoring for depressive Patient's Trial) [ISRCTN66386086]—study protocol. BMC Public Health. 2005;5:101. International. [pmid: 16207375].
299 Gertler R, Kopec-Schrader EM, Blackwell CJ. Evolution and evaluation of a medical psychiatric unit. General Hospital Psychiatry. Jan. 1995;17(1):26-31. Not primary care setting. [pmid: 7737491].
300 Gilbody S, House AO, Sheldon TA. Screening and case finding instruments for depression Cochrane Database of Systematic Reviews 2005; (4):CD002792. Not integrated care
301 Gilbody S, Whitty P. Improving the recognition and management of depression in primary care. Effective Health Care. 2002;7(5):1-11. Not on target, other publication type.
302 Ginsberg G, Marks I, Waters H. Cost-benefit analysis of a controlled trial of nurse therapy for neuroses in primary care. Psychological Medicine. Aug. 1984;14(3):683-90. International. [pmid: 6436855].
303 Glanz A. Findings of a national survey of the role of general practitioners in the treatment of opiate misuse: dealing with the opiate misuser. British Medical Journal Clinical Research Ed. Aug 23. 1986;293(6545):486-8. Not integrated care. [pmid: 3091174].
304 Glasgow RE, Price DW. Individualised treatment improves depression in people with depression and diabetes. Evidence-Based Mental Health. May. 2005;8(2):40. International. [pmid: 15851803].
305 Godard C, Chevalier A, Lecrubier Y, et al. APRAND programme: an intervention to prevent relapses of anxiety and depressive disorders. First results of a medical health promotion intervention in a population of employees. European Psychiatry: the Journal of the Association of European Psychiatrists. Oct. 2006;21(7):451-9. International. [pmid: 16675204].
306 Godding V, Kruth M, Jamart J. Joint consultation for high-risk asthmatic children and their families, with pediatrician and child psychiatrist as co-therapists: model and evaluation. Family Process. Sep. 1997;36(3):265-80. Not integrated care. [pmid: 9439938].
307 Godley MD, Godley SH, Dennis ML, et al. Preliminary outcomes from the assertive continuing care experiment for adolescents discharged from residential treatment. Journal of Substance Abuse Treatment. Jul. 2002;23(1):21-32. Not primary care setting. [pmid: 12127465].
308 Godley SH, Godley MD, Pratt A, et al. Case management services for adolescent substance abusers: a program description. Journal of Substance Abuse Treatment. Jul–Aug. 1994;11(4):309-17. Not primary care setting. [pmid: 7966501].
309 Goering P. Collaborative care speeds recovery from depression. Evidence-Based Mental Health. Nov. 2003;6(4):116. International. [pmid: 14585789].
310 Goldberg D. Cost-effectiveness studies in the evaluation of mental health services in the community: current knowledge and unsolved problems. International Clinical Psychopharmacology. Jan. 1995;9(Suppl 5):29-34. Not primary care setting. [pmid: 7622831].
311 Goldberg D. The “NICE Guideline” on the treatment of depression. Epidemiologia e Psichiatria Sociale. Jan–Mar. 2006;15(1):11-5. International. [pmid: 16584098].
312 Goldberg D, Kay C, Thompson L. Psychiatric morbidity in general practice and the community. Psychological Medicine. Nov. 1976;6(4):565-9. Not integrated care. [pmid: 1005572].
313 Gonzalez J, Williams JW J, Noel PH, et al. Adherence to mental health treatment in a primary care clinic. Journal of the American Board of Family Practice. Mar–Apr. 2005;18(2):87-96. Not integrated care. [pmid: 15798137].
314 Gottlieb NH, Mullen PD, McAlister AL. Patients' substance abuse and the primary care physician: patterns of practice. Addictive Behaviors. 1987;12(1):23-32. Not integrated care. [pmid: 3565109].
315 Goudreau J, Duhamel F, Ricard N. The impact of a family systems nursing educational program on the practice of psychiatric nurses: a pilot study. Journal of Family Nursing. Aug. 2006;12(3):292-306. Not integrated care. [pmid: 16837696].
316 Gournay K, Brooking J. Community psychiatric nurses in primary health care.[see comment]. British Journal of Psychiatry. Aug. 1994;165(2):231-8. International. [pmid: 7953038].
317 Gournay K, Denford L, Parr AM, et al. British nurses in behavioural psychotherapy: a 25-year follow-up. Journal of Advanced Nursing. Aug. 2000;32(2):343-51. International. [pmid: 10964181].
318 Granier S, Owen P, Pill R, et al. Recognising meningococcal disease in primary care: qualitative study of how general practitioners process clinical and contextual information. BMJ. Jan 24. 1998;316(7127):276-9. Not mental health condition. [pmid: 9472513].
319 Grant C, Goodenough T, Harvey I, et al. A randomised controlled trial and economic evaluation of a referrals facilitator between primary care and the voluntary sector.[see comment]. BMJ. Feb 12. 2000;320(7232):419-23. International. [pmid: 10669447].
320 Graugaard PK, Holgersen K, Finset A. Communicating with alexithymic and non-alexithymic patients: an experimental study of the effect of psychosocial communication and empathy on patient satisfaction. Psychotherapy & Psychosomatics. Mar–Apr. 2004;73(2):92-100. Not mental health condition. [pmid: 14767151].
321 Grawe RW, Falloon IR, Widen JH, et al. Two years of continued early treatment for recent-onset schizophrenia: a randomised controlled study. Acta Psychiatrica Scandinavica. Nov. 2006;114(5):328-36. International. [pmid: 17022792].
322 Gray GE. Integrated medical care in a mental health clinic improved quality of care and outcomes in serious mental disorders. Evidence-Based Mental Health. May. 2002;5(2):46. International. [pmid: 12026895].
323 Grebely J, Genoway K, Khara M, et al. Treatment uptake and outcomes among current and former injection drug users receiving directly observed therapy within a multidisciplinary group model for the treatment of hepatitis C virus infection. International Journal of Drug Policy. Oct. 2007;18(5):437-43. Not mental health condition. [pmid: 17854734].
324 Greenberg DB. Barriers to the treatment of depression in cancer patients Journal of the National Cancer Institute 2004; Monographs.(32):127–35. Not primary care setting
325 Grembowski DE, Martin D, Patrick DL, et al. Managed care, access to mental health specialists, and outcomes among primary care patients with depressive symptoms. Journal of General Internal Medicine. Apr. 2002;17(4):258-69. Not integrated care. [pmid: 11972722].
326 Griffiths HS, Wilson MA, Kincey JA. Anxiety levels, patient satisfaction and failed appointment rate in anxious patients referred by general practitioners to a dental hospital unit.[see comment]. British Dental Journal. Aug 8. 1998;185(3):134-6. Not integrated care. [pmid: 9744238].
327 Grigg M, Herrman H, Harvey C. What is duty/triage? Understanding the role of duty/triage in an area mental health service. Australian & New Zealand Journal of Psychiatry. Dec. 2002;36(6):787-91. Not integrated care. [pmid: 12406121].
328 Griswold KS, Servoss TJ, Leonard KE, et al. Connections to primary medical care after psychiatric crisis. Journal of the American Board of Family Practice. May–Jun. 2005;18(3):166-72. Not primary care setting. [pmid: 15879563].
329 Group BS. Responses of primary health care professionals to UK national guidelines on the management and referral of women with breast conditions. Journal of Evaluation in Clinical Practice. Aug. 2002;8(3):319-25. Not mental health condition. [pmid: 12164978].
330 Grunfeld E, Mant D, Yudkin P, et al. Routine follow up of breast cancer in primary care: randomised trial.[see comment]. BMJ. Sep 14. 1996;313(7058):665-9. Not mental health condition. [pmid: 8811760].
331 Gunn J, Lumley J, Chondros P, et al. Does an early postnatal check-up improve maternal health: results from a randomised trial in Australian general practice. British Journal of Obstetrics & Gynaecology. Sep. 1998;105(9):991-7. Not integrated care. [pmid: 9763051].
332 Gunnell D, Bennewith O, Peters TJ, et al. Do patients who self-harm consult their general practitioner soon after hospital discharge? A cohort study. Social Psychiatry & Psychiatric Epidemiology. Dec. 2002;37(12):599-602. Not primary care setting. [pmid: 12545238].
333 Gunnell D, Martin RM. Patterns of General Practitioner consultation for mental illness by young people in rural areas. Health Statistics Quarterly 2004; (21):30–3. Not integrated care
334 Guralnick MJ, Bennett FC, Heiser KE, et al. Training residents in developmental pediatrics: results from a national replication. Journal of Developmental & Behavioral Pediatrics. Oct. 1987;8(5):260-5. Not mental health condition. [pmid: 2445783].
335 Haber JS. Early diagnosis and referral of children with developmental disabilities. American Family Physician. Jan. 1991;43(1):132-40. Not mental health condition. [pmid: 1702577].
336 Habib A, Sanchez M, Pervez R, et al. Compliance with disposition to primary care physicians and psychiatrists in elderly homebound mentally ill patients. American Journal of Geriatric Psychiatry. 1998;6(4):290-5. Not primary care setting. [pmid: 9793577].
337 Hales RE, Borus JF. Teaching psychosocial issues to medical house staff: a liaison program on an oncology service. General Hospital Psychiatry. Apr. 1982;4(1):1-6. Not primary care setting. [pmid: 7075949].
338 Hallam L. How involuntary commitment impacts on the burden of care of the family. International Journal of Mental Health Nursing. Aug. 2007;16(4):247-56. Not integrated care. [pmid: 17635624].
339 Hamilton W, Sharp DJ, Peters TJ, et al. Clinical features of prostate cancer before diagnosis: a population-based, case-control study. British Journal of General Practice. Oct. 2006;56(531):756-62. Not mental health condition. [pmid: 17007705].
340 Hansen MS, Fink P, Frydenberg M, et al. Mental disorders among internal medical inpatients: prevalence, detection, and treatment status. Journal of Psychosomatic Research. Apr. 2001;50(4):199-204. Not primary care setting. [pmid: 11369025].
341 Hansson L, Christiansen L, Sandlund M, et al. The Nordic Comparative Study on Sectorized Psychiatry. Part V. Social Psychiatry & Psychiatric Epidemiology. Jan. 1997;32(1):12-8. Not integrated care. [pmid: 9029982].
342 Harmon K, Carr VJ, Lewin TJ. Comparison of integrated and consultation-liaison models for providing mental health care in general practice in New South Wales. Australia Journal of Advanced Nursing. Dec. 2000;32(6):1459-66. International. [pmid: 11136414].
343 Harris M, Ferreira A, Moraes I, et al. Reply letter utilization by secondary level specialists in a municipality in Brazil: a qualitative study. Pan American Journal of Public Health. Feb–Mar. 2007;21(23):96-110. International. [pmid: 17565797].
344 Harris MF, Hobbs C, Powell Davies G, et al. Implementation of a SNAP intervention in two divisions of general practice: a feasibility study. Medical Journal of Australia. Nov 21. 2005;183(10 Suppl):S54-8. International. [pmid: 16296953].
345 Harris MF, Silove D, Kehag E, et al. Anxiety and depression in general practice patients: prevalence and management.[see comment]. Medical Journal of Australia. May 6. 1996;164(9):526-9. Not integrated care. [pmid: 8649286].
346 Hasan MK, Shellhorse M. Mental health reform: a practical approach. West Virginia Medical Journal. Jan–Feb. 1996;92(1):14-7. Not on target, other publication type. [pmid: 8599241].
347 Hasseler M, Gorres S, Altmann N, et al. A possible way out of poor healthcare resulting from demographic problems: need-orientated home-based-nursing-care and nursing-home-care. Journal of Nursing Management. Sep. 2006;14(6):455-61. Not integrated care. [pmid: 16919123].
348 Heatley C, Ricketts T, Forrest J. Training general practitioners in cognitive behavioural therapy for panic disorder: randomized-controlled trial. Journal of Mental Health. Feb. 2005;14(1):73-82. International.
349 Hegel MT, Dietrich AJ, Seville JL, et al. Training residents in problem-solving treatment of depression: a pilot feasibility and impact study. Family Medicine. Mar. 2004;36(3):204-8. Medical education. [pmid: 14999578].
350 Heisel MJ, Duberstein PR. Suicide Prevention in Older Adults Clinical Psychology. Science and Practice. Fal. 2005;12(3):242-59. Not integrated care.
351 Heisey R, Mahoney L, Watson B. Management of palpable breast lumps. Consensus guideline for family physicians.[see comment]. Canadian Family Physician. Aug. 1999;45:1926-32. Not mental health condition. [pmid: 10463093].
352 Hemmings A. Counselling in primary care: a randomised controlled trial. Patient Education & Counseling. Nov. 1997;32(3):219-30. International. [pmid: 9423503].
353 Henderson DC, Mollica RF, Tor S, et al. Building primary care practitioners' attitudes and confidence in mental health skills in a post-conflict society: a Cambodian example. Journal of Nervous & Mental Disease. Aug. 2005;193(8):551-9. International. [pmid: 16082300].
354 Hendriksen H, Harrison RA. Occupational therapy in accident and emergency departments: a randomized controlled trial. Journal of Advanced Nursing. Dec. 2001;36(6):727-32. Not primary care setting. [pmid: 11903702].
355 Heneghan AM, Chaudron LH, Storfer-Isser A, et al. Factors associated with identification and management of maternal depression by pediatricians.[see comment]. Pediatrics. Mar. 2007;119(3):444-54. Not integrated care. [pmid: 17332196].
356 Heyman B, Swain J, Gillman M. Organisational simplification and secondary complexity in health services for adults with learning disabilities. Social Science & Medicine. Jan. 2004;58(2):357-67. Not mental health condition. [pmid: 14604621].
357 Heywood PL, Blackie GC, Cameron IH, et al. An assessment of the attributes of frequent attenders to general practice. Family Practice. Jun. 1998;15(3):198-204. Not integrated care. [pmid: 9694175].
358 Hickie IB, Davenport TA, Ricci CS. Screening for depression in general practice and related medical settings. Medical Journal of Australia. Oct 7. 2002;177(Suppl):S111-6. Not integrated care. [pmid: 12358569].
359 Higginbotham N, Connor L. Professional ideology and the construction of western psychiatry in Southeast Asia. International Journal of Health Services. 1989;19(1):63-78. International. [pmid: 2925301].
360 Higgins R. Implementing case management in mental health services. Journal of Nursing Management. Jan. 1994;2(1):25-30. Not primary care setting. [pmid: 7952686].
361 Hill BC, Theis GA, Davison MA. Integration of a Web-based behavioral health assessment tool in clinical medicine. American Clinical Laboratory. Apr. 2002;21(3):21-5. Not on target, other publication type. [pmid: 12038081].
362 Hill-Briggs F, Gary TL, Bone LR, et al. Medication adherence and diabetes control in urban African Americans with type 2 diabetes. Health Psychology. Jul. 2005;24(4):349-57. Not integrated care. [pmid: 16045370].
363 Hillemeier MM, Weisman CS, Baker K, et al. Mental health services provided through the National Centers of Excellence in Women's Health: do they reach rural women?. Womens Health Issues. Sep–Oct. 2005;15(5):224-9. Not integrated care. [pmid: 16165008].
364 Hilty DM, Ingraham RL, Yang SP, et al. Multispecialty telephone and e-mail consultation for patients with developmental disabilities in rural California. Telemedicine Journal & E-Health. 2004;10(4):413-21. Not mental health condition. [pmid: 15689644].
365 Hilty DM, Yellowlees PM, Cobb HC, et al. Models of telepsychiatric consultation—liaison service to rural primary care. Psychosomatics. Mar–Apr. 2006;47(2):152-7. Not on target, other publication type. [pmid: 16508028].
366 Hilty DM, Yellowlees PM, Nesbitt TS. Evolution of telepsychiatry to rural sites: changes over time in types of referral and in primary care providers' knowledge, skills and satisfaction. General Hospital Psychiatry. Sep–Oct. 2006;28(5):367-73. Not included study design. [pmid: 16950370].
367 Hinze SW. The intra-occupational sex segregation of physicians: Why gender matters Hinze, Susan Waldoch: Vanderbilt U, US; 1996. Not integrated care
368 Hirschfeld RMA. Why care about bipolar disorder? A primary care physicians' guide to screening and referral. Advanced Studies in Medicine. Apr. 2003;3(4):223-7. Not on target, other publication type.
369 Hobbs H, Wilson JH, Archie S. The Alumni program: redefining continuity of care in psychiatry. Journal of Psychosocial Nursing & Mental Health Services. Jan. 1999;37(1):23-9. International. [pmid: 9921462].
370 Hobbs H, Wilson JH, Archie S. Evaluation of the Alumni Program. A shared-care model for psychosis. Journal of Psychosocial Nursing & Mental Health Services. Jan. 2004;42(1):28-36. International. [pmid: 14768277].
371 Hollows P, McAndrew PG, Perini MG. Delays in the referral and treatment of oral squamous cell carcinoma. [erratum appears in Br Dent J 2000 Apr 8;188(7):380]. British Dental Journal. Mar 11. 2000;188(5):262-5. Not mental health condition. [pmid: 10758688].
372 Holmberg SA, Thelin AG. Primary care consultation, hospital admission, sick leave and disability pension owing to neck and low back pain: a 12-year prospective cohort study in a rural population. BMC Musculoskeletal Disorders. 2006;7:66. Not integrated care. [pmid: 16907991].
373 Honigfeld L, McKay K. Barriers to enhancing practice-based developmental services. Journal of Developmental & Behavioral Pediatrics. Feb. 2006;27(1 Suppl):S30-3. discussion S4–7. not mental health condition. [pmid: 16715789].
374 Hoppe SK, Leon RL, Realini JP. Depression and anxiety among Mexican Americans in a family health center. Social Psychiatry & Psychiatric Epidemiology. Mar. 1989;24(2):63-8. Not integrated care. [pmid: 2499054].
375 Horn SD. Limiting access to psychiatric services can increase total health care costs. Journal of Clinical Psychiatry. 2003;64(Suppl 17):23-8. Not on target, other publication type. [pmid: 14680424].
376 Houghton S, Saxon D. An evaluation of large group CBT psycho-education for anxiety disorders delivered in routine practice. Patient Education & Counseling. Sep. 2007;68(1):107-10. International. [pmid: 17582724].
377 Howe A, Bath P, Goudie F, et al. Getting the questions right: an example of loss of validity during transfer of a brief screening approach for depression in the elderly. International Journal of Geriatric Psychiatry. Jul. 2000;15(7):650-5. Not integrated care. [pmid: 10918347].
378 Hroscikoski MC, Solberg LI, Sperl-Hillen JM, et al. Challenges of change: a qualitative study of chronic care model implementation. Annals of Family Medicine. Jul–Aug. 2006;4(4):317-26. Not on target, other publication type. [pmid: 16868235].
379 Hurry J, Bebbington PE, Tennant C. Psychiatric symptoms, social disablement and illness behaviour. Australian & New Zealand Journal of Psychiatry. Mar. 1987;21(1):68-73. Not integrated care. [pmid: 3476111].
380 Hurst NP, Lambert CM, Forbes J, et al. Does waiting matter? A randomized controlled trial of new non-urgent rheumatology out-patient referrals.[see comment]. Rheumatology. Apr. 2000;39(4):369-76. Not mental health condition. [pmid: 10817768].
381 Hutchinson SJ, Taylor A, Gruer L, et al. One-year follow-up of opiate injectors treated with oral methadone in a GP-centred programme. Addiction. Jul. 2000;95(7):1055-68. Not mental health condition. [pmid: 10962770].
382 Huxley P, Raval H, Korer J, et al. Psychiatric morbidity in the clients of social workers: clinical outcome. Psychological Medicine. Feb. 1989;19(1):189-97. Not integrated care. [pmid: 2727206].
383 Hyvonen S, Nikkonen M. Primary health care practitioners' tools for mental health care. Journal of Psychiatric & Mental Health Nursing. Oct. 2004;11(5):514-24. International. [pmid: 15450017].
384 Iliffe S, De Lepeleire J, Van Hout H, et al. Understanding obstacles to the recognition of and response to dementia in different European countries: a modified focus group approach using multinational, multi-disciplinary expert groups. Aging & Mental Health. Jan. 2005;9(1):1-6. Not integrated care. [pmid: 15841826].
385 Iliffe S, Wilcock J, Haworth D. Obstacles to shared care for patients with dementia: a qualitative study. Family Practice. Jun. 2006;23(3):353-62. International. [pmid: 16461450].
386 Iliffe S, Wilcock J, Haworth D. Delivering psychosocial interventions for people with dementia in primary care: Jobs or skills?. Dementia: The International Journal of Social Research and Practice. Aug. 2006;5(3):327-38. International.
387 Inouye SK. Delirium after hip fracture: to be or not to be?[see comment][comment]. Journal of the American Geriatrics Society. May. 2001;49(5):678-9. Not mental health condition. [pmid: 11380767].
388 Isles CG, Walker LM, Beevers GD, et al. Mortality in patients of the Glasgow Blood Pressure Clinic. Journal of Hypertension. Apr. 1986;4(2):141-56. Not mental health condition. [pmid: 3711657].
389 Ito M. ‘Nurturing the brain’ as an emerging research field involving child neurology. Brain & Development. Oct. 2004;26(7):429-33. Not mental health condition. [pmid: 15351077].
390 Ives TJ, Chelminski PR, Hammett-Stabler CA, et al. Predictors of opioid misuse in patients with chronic pain: a prospective cohort study. BMC Health Services Research. 2006;6:46. Not mental health condition. [pmid: 16595013].
391 Jackson G, Gater R, Goldberg D, et al. A new community mental health team based in primary care. A description of the service and its effect on service use in the first year. British Journal of Psychiatry. Mar. 1993;162:375-84. International. [pmid: 8453434].
392 Jacobs JL, Damson LC, Rogers DE. One approach to care for patients infected with human immunodeficiency virus in an academic medical center Bulletin of the New York. Academy of Medicine. 1996;73(2):301-13. Not mental health condition.
393 Jacobs JT. Treatment of depressive disorders in split versus integrated therapy and comparisons of prescriptive practices of psychiatrists and advanced practice registered nurses. Archives of Psychiatric Nursing. Dec. 2005;19(6):256-63. Not integrated care. [pmid: 16308125].
394 Jansen AP, van Hout HP, van Marwijk HW, et al. (Cost)-effectiveness of case-management by district nurses among primary informal caregivers of older adults with dementia symptoms and the older adults who receive informal care: design of a randomized controlled trial [ISCRTN83135728]. BMC Public Health. 2005;5:133. Not integrated care. [pmid: 16343336].
395 Jansson LM, Svikis D, Lee J, et al. Pregnancy and addiction. A comprehensive care model. Journal of Substance Abuse Treatment. Jul–Aug. 1996;13(4):321-9. Not integrated care. [pmid: 9076650].
396 Jarvis A, McIntosh G. The recognition and support of carers. Professional Nurse. Dec. 2004;20(4):24-6. Not mental health condition.
397 Javorsky J. Integration of partial hospitalization and inpatient child/adolescent psychiatric units: “A question of continuity of care”. International Journal of Partial Hospitalization. Jun. 1992;8(1):65-75. Not primary care setting. [pmid: 10120296].
398 Johansson EE, Hamberg K, Lindgren G, et al. “I've been crying my way”—qualitative analysis of a group of female patients' consultation experiences. Family Practice. Dec. 1996;13(6):498-503. Not integrated care. [pmid: 9023524].
399 Johnston BD, Huebner CE, Anderson ML, et al. Healthy steps in an integrated delivery system: child and parent outcomes at 30 months. Archives of Pediatrics & Adolescent Medicine. Aug. 2006;160(8):793-800. Not integrated care. [pmid: 16894077].
400 Johnstone A, Goldberg D. Psychiatric screening in general practice. A controlled trial Lancet. Mar 20. 1976;1(7960):605-8. Not integrated care. [pmid: 55891].
401 Jolly K, Bradley F, Sharp S, et al. Randomised controlled trial of follow up care in general practice of patients with myocardial infarction and angina: final results of the Southampton heart integrated care project (SHIP). BMJ. Mar 13. 1999;318(7185):706-11. International. [pmid: 10074017].
402 Jones GT, Macfarlane GJ. Epidemiology of low back pain in children and adolescents. Archives of Disease in Childhood. Mar. 2005;90(3):312-6. Not mental health condition. [pmid: 15723927].
403 Jones LR, Mabe PA, Riley WT. Physician interpretation of illness behavior. International Journal of Psychiatry in Medicine. 1989;19(3):237-48. Not integrated care. [pmid: 2807743].
404 Jonge PD, Zomerdijk MM, Huyse FJ, et al. Mental disturbances and perceived complexity of nursing care in medical inpatients: results from a European study. Journal of Advanced Nursing. Nov. 2001;36(3):355-63. Not primary care setting. [pmid: 11686750].
405 Jordan K, Jinks C, Croft P. A prospective study of the consulting behaviour of older people with knee pain. British Journal of General Practice. Apr. 2006;56(525):269-76. Not mental health condition. [pmid: 16611515].
406 Joubert J, Reid C, Joubert L, et al. Risk factor management and depression post-stroke: the value of an integrated model of care. Journal of Clinical Neuroscience. Jan. 2006;13(1):84-90. International. [pmid: 16410202].
407 Juang YY, Liu CY, Chen CY, et al. Geropsychiatric consultation in a general hospital in Taiwan. Psychiatry & Clinical Neurosciences. Jun. 2005;59(3):240-5. Not primary care setting. [pmid: 15896215].
408 Judd F, Cockram A, Davis J, et al. First year of practice visits for the Rural Depression Anxiety Research and Treatment General Practice program. Australian Journal of Rural Health. Aug. 2003;11(4):175-80. International. [pmid: 14641229].
409 Kadam UT, Thomas E, Croft PR. Is chronic widespread pain a predictor of all-cause morbidity? A 3 year prospective population based study in family practice. Journal of Rheumatology. Jul. 2005;32(7):1341-8. Not mental health condition. [pmid: 15996075].
410 Kaeser AC, Cooper B. The psychiatric patient, the general practitioner, and the outpatient clinic: an operational study and a review. Psychological Medicine. Aug. 1971;1(4):312-25. International. [pmid: 5149873].
411 Kahana E, Kahana B. Therapeutic potential of age integration. Effects of age-integrated hospital environments on elderly psychiatric patients. Archives of General Psychiatry. Jul. 1970;23(1):20-9. Not primary care setting. [pmid: 5447373].
412 Kapur N, Hunt I, Lunt M, et al. Psychosocial and illness related predictors of consultation rates in primary care—a cohort study. Psychological Medicine. May. 2004;34(4):719-28. Not integrated care. [pmid: 15099425].
413 Kapur N, Hunt I, Lunt M, et al. Primary care consultation predictors in men and women: a cohort study. British Journal of General Practice. Feb. 2005;55(511):108-13. Not integrated care. [pmid: 15720931].
414 Kashner TM, Rost K, Smith GR, et al. An analysis of panel data. The impact of a psychiatric consultation letter on the expenditures and outcomes of care for patients with somatization disorder. Medical Care. Sep. 1992;30(9):811-21. Not on target, other publication type. [pmid: 1518313].
415 Kasper S, Muller-Spahn F. Intravenous antidepressant treatment: focus on citalopram. European Archives of Psychiatry & Clinical Neuroscience. Jun. 2002;252(3):105-9. Not integrated care. [pmid: 12192466].
416 Katerndahl DA, Parchman M. The ability of the stress process model to explain mental health outcomes. Comprehensive Psychiatry. Sep–Oct. 2002;43(5):351-60. Not integrated care. [pmid: 12216010].
417 Katerndahl DA, Trammell C. Prevalence and recognition of panic states in STARNET patients presenting with chest pain. Journal of Family Practice. Jul. 1997;45(1):54-63. Not integrated care. [pmid: 9228915].
418 Kates N, Craven M, Crustolo AM, et al. Integrating mental health services within primary care. A Canadian program. General Hospital Psychiatry. Sep. 1997;19(5):324-32. International. [pmid: 9328777].
419 Kates N, Crustolo AM, Farrar S, et al. Mental health care and nutrition. Integrating specialist services into primary care. Canadian Family Physician. Dec. 2002;48:1898-903. International. [pmid: 12520789].
420 Kates N, Mach M. Chronic disease management for depression in primary care: a summary of the current literature and implications for practice.[see comment]. Canadian Journal of Psychiatry - Revue Canadienne de Psychiatrie. Feb. 2007;52(2):77-85. Not on target, other publication type. [pmid: 17375862].
421 Katon W, Gonzales J. A review of randomized trials of psychiatric consultation-liaison studies in primary care. Psychosomatics. May–Jun. 1994;35(3):268-78. Not on target, other publication type. [pmid: 8036256].
422 Katon W, Unutzer J. Collaborative care models for depression: time to move from evidence to practice.[comment]. Archives of Internal Medicine. Nov 27. 2006;166(21):2304-6. Not on target, other publication type. [pmid: 17130381].
423 Katon W, Von Korff M, Lin E, et al. Distressed high utilizers of medical care. DSM-III-R diagnoses and treatment needs. General Hospital Psychiatry. Nov. 1990;12(6):355-62. Not integrated care. [pmid: 2245919].
424 Katon W, Von Korff M, Lin E, et al. Collaborative management to achieve depression treatment guidelines. Journal of Clinical Psychiatry. 1997;58(Suppl 1):20-3. Not on target, other publication type. [pmid: 9054905].
425 Katon W, Williamson P, Ries R. A prospective study of 60 consecutive psychiatric consultations in a family medicine clinic. Journal of Family Practice. Jul. 1981;13(1):47-56. Not integrated care. [pmid: 7252438].
426 Katon WJ. The development of a randomized trial of consultation-liaison psychiatry trial in distressed high utilizers of primary care. Psychiatric Medicine. 1991;9(4):577-91. Not on target, other publication type. [pmid: 1749840].
427 Katon WJ, von Korff M, Lin E, et al. Methodologic issues in randomized trials of liaison psychiatry in primary care. Psychosomatic Medicine. Mar–Apr. 1994;56(2):97-103. Not on target, other publication type. [pmid: 8008804].
428 Kazdin AE. A model for developing effective treatments: progression and interplay of theory, research, and practice. Journal of Clinical Child Psychology. Jun. 1997;26(2):114-29. Not integrated care. [pmid: 9169373].
429 Kazis LE, Miller DR, Skinner KM, et al. Patient-reported measures of health: The Veterans Health Study.[see comment]. Journal of Ambulatory Care Management. Jan–Mar. 2004;27(1):70-83. Not integrated care. [pmid: 14717468].
430 Keatinge D, Gilmore V. Shared care: a partnership between parents and nurses. Australian Journal of Advanced Nursing. Sep–Nov. 1996;14(1):28-36. Not mental health condition. [pmid: 9128467].
431 Kehoe RF, Mander AJ. Lithium treatment: prescribing and monitoring habits in hospital and general practice.[see comment]. BMJ. Feb 29. 1992;304(6826):552-4. Not integrated care. [pmid: 1559064].
432 Kelly RB. Controlled trial of a time-efficient method of health promotion. American Journal of Preventive Medicine. Jul–Aug. 1988;4(4):200-7. Not mental health condition. [pmid: 3166825].
433 Kendrick T, Burns T, Freeling P. Randomised controlled trial of teaching general practitioners to carry out structured assessments of their long term mentally ill patients. BMJ. Jul 8. 1995;311(6997):93-8. International. [pmid: 7613410].
434 Kendrick T, Simons L, Mynors-Wallis L, et al. A trial of problem-solving by community mental health nurses for anxiety, depression and life difficulties among general practice patients. The CPN-GP study. Health Technology Assessment (Winchester, England). Sep. 2005;9(37):1-104. International.
435 Kendrick T, Simons L, Mynors-Wallis L, et al. Cost-effectiveness of referral for generic care or problem-solving treatment from community mental health nurses, compared with usual general practitioner care for common mental disorders: Randomised controlled trial. British Journal of Psychiatry. Jul. 2006;189:50-9. International. [pmid: 16816306].
436 Kennedy A, Nelson E, Reeves D, et al. A randomised controlled trial to assess the impact of a package comprising a patient-orientated, evidence-based self-help guidebook and patient-centred consultations on disease management and satisfaction in inflammatory bowel disease. Health Technology Assessment (Winchester, England). 2003;7(28):iii. Not primary care setting.
437 Kennedy C, Yellowlees P. The effectiveness of telepsychiatry measured using the Health of the Nation Outcome Scale and the Mental Health Inventory. Journal of Telemedicine & Telecare. 2003;9(1):12-6. International. [pmid: 12641887].
438 Kenyon R, West D, Raistrick D, et al. General practitioner satisfaction with ‘shared care’ working. Journal of Substance Use. 2001;6(1):36-9. International.
439 Kerry S, Hilton S, Dundas D, et al. Radiography for low back pain: a randomised controlled trial and observational study in primary care.[see comment]. British Journal of General Practice. Jun. 2002;52(479):469-74. Not mental health condition. [pmid: 12051211].
440 Kersun LS, Kazak AE. Prescribing practices of selective serotonin reuptake inhibitors (SSRIs) among pediatric oncologists: a single institution experience. Pediatric Blood & Cancer. Sep. 2006;47(3):339-42. Not integrated care. [pmid: 16007589].
441 Kessel N, Hore BD, Makenjuola JD, et al. The Manchester detoxification service. Description and evaluation Lancet. Apr 14. 1984;1(8381):839-42. Not integrated care. [pmid: 6143149].
442 Kessler D, Bennewith O, Lewis G, et al. Detection of depression and anxiety in primary care: follow up study. BMJ. Nov 2. 2002;325(7371):1016-7. [pmid: 12411363].
443 Khalsa J, Vocci F, Altice F, et al. Buprenorphine and HIV primary care: new opportunities for integrated treatment. Clinical Infectious Diseases. Dec 15. 2006;43(Suppl 4):S169-72. Not mental health condition. [pmid: 17109302].
444 Kielan K, Kucharska-Pietura K, Warchala A, et al. The integration of the computer advisory system together with neuroimaging procedures, neurophysiological markers and psychological cognitive tests in order to obtain evidence based system for the physician treating affective disturbance. Wiadomosci Lekarskie. 2004;57(Suppl 1):158-62. Not on target, other publication type. [pmid: 15884229].
445 Kilbourne AM, Schulberg HC, Post EP, et al. Translating evidence-based depression management services to community-based primary care practices. Milbank Quarterly. 2004;82(4):631-59. Not on target, other publication type. [pmid: 15595945].
446 Killaspy H, Banerjee S, King M, et al. Non-attendance at psychiatric outpatient clinics: communication and implications for primary care.[see comment]. British Journal of General Practice. Nov. 1999;49(448):880-3. Not integrated care. [pmid: 10818652].
447 Kindy D. Ongoing primary care intervention increased remission and emotional and physical role functioning in major depression. Evidence-Based Nursing. Jul. 2003;6(3):86. International. [pmid: 12882199].
448 King MB. Psychological and social problems in HIV infection: interviews with general practitioners in London. BMJ. Sep 16. 1989;299(6701):713-7. International. [pmid: 2508884].
449 King VL, Kidorf MS, Stoller KB, et al. A 12-month controlled trial of methadone medical maintenance integrated into an adaptive treatment model. Journal of Substance Abuse Treatment. Dec. 2006;31(4):385-93. Not mental health condition. [pmid: 17084792].
450 Kinzie JD, Char WF, Markoff RA, et al. Objectives of psychiatric education in a primary care curriculum. Journal of Medical Education. Aug. 1977;52(8):664-7. Medical education. [pmid: 886573].
451 Kirkcaldy RD, Tynes LL. Depression screening in a VA primary care clinic. Psychiatric Services. Dec. 2006;57(12):1694-6. not integrated care. [pmid: 17158481].
452 Kisely S, Duerden D, Shaddick S, et al. Collaboration between primary care and psychiatric services: does it help family physicians?. Canadian Family Physician. Jul. 2006;52:876-7. International. [pmid: 17273487].
453 Kisely S, Horton-Hausknecht J, Miller K, et al. Increased collaboration between primary care and psychiatric services. A survey of general practitioners' views and referrals. Australian Family Physician. Jun. 2002;31(6):587-9. International. [pmid: 12154610].
454 Kisely S, Simon G. An international study comparing the effect of medically explained and unexplained somatic symptoms on psychosocial outcome. Journal of Psychosomatic Research. Feb. 2006;60(2):125-30. Not integrated care. [pmid: 16439264].
455 Knight L. How do GPs make referral and treatment decisions when patients present with mental health problems?. Counselling Psychology Quarterly. Sep. 2003;16(3):195-221. Not integrated care.
456 Knott A, Dieperink E, Willenbring ML, et al. Integrated psychiatric/medical care in a chronic hepatitis C clinic: effect on antiviral treatment evaluation and outcomes. American Journal of Gastroenterology. Oct. 2006;101(10):2254-62. Not primary care setting. [pmid: 17032190].
457 Kobak KA, Greist JH, Jefferson JW, et al. Decision support for patient care: computerized rating scales. Behavioral Healthcare Tomorrow. Feb. 1996;5(1):25-9. Not on target, other publication type. [pmid: 10158444].
458 Kobak KA, Taylor LH, Dottl SL, et al. A computer-administered telephone interview to identify mental disorders.[see comment]. JAMA. Sep 17. 1997;278(11):905-10. Not integrated care. [pmid: 9302242].
459 Koopmans GT, Meeuwesen L, Huyse FJ, et al. Effects of psychiatric consultation on medical consumption in medical outpatients with low back pain. General Hospital Psychiatry. May. 1996;18(3):145-54. International. [pmid: 8739008].
460 Kopelowicz A, Liberman RP. Integrating treatment with rehabilitation for persons with major mental illnesses. Psychiatric Services. Nov. 2003;54(11):1491-8. Not primary care setting. [pmid: 14600308].
461 Kovess V, Gysens S, Poinsard R, et al. Mental health and use of care in people receiving a French social benefit. Social Psychiatry & Psychiatric Epidemiology. Nov. 1999;34(11):588-94. Not integrated care. [pmid: 10651177].
462 Kravitz RL, Epstein RM, Feldman MD, et al. Influence of patients' requests for direct-to-consumer advertised antidepressants: a randomized controlled trial. JAMA: Journal of the American Medical Association. Apr 27. 2005;293(16):1995-2002. Not integrated care. [pmid: 15855433].
463 Kravitz RL, Franks P, Feldman M, et al. What drives referral from primary care physicians to mental health specialists? A randomized trial using actors portraying depressive symptoms. Journal of General Internal Medicine. Jun. 2006;21(6):584-9. Not integrated care. [pmid: 16808740].
464 Kreipe RE, Yussman SM. The role of the primary care practitioner in the treatment of eating disorders Adolescent Medicine State of the. Art Reviews. Feb. 2003;14(1):133-47. Not on target, other publication type.
465 Krumholz HM, Currie PM, Riegel B, et al. A taxonomy for disease management: a scientific statement from the American Heart Association Disease Management Taxonomy Writing Group. Circulation. Sep 26. 2006;114(13):1432-45. Not mental health condition. [pmid: 16952985].
466 Kumpers S, Mur I, Maarse H, et al. A comparative study of dementia care in England and the Netherlands using neo-institutionalist perspectives. Qualitative Health Research. Nov. 2005;15(9):1199-230. Not mental health condition. [pmid: 16204401].
467 Kunyk D, Els C, Predy G, et al. Development and introduction of a comprehensive tobacco control policy in a Canadian regional health authority. Preventing Chronic Disease. Apr. 2007;4(2):A30. Not mental health condition. [pmid: 17362621].
468 Kurg-Cringle R, Blake LA, Dunham D, et al. A nurse-managed inpatient program for patients with chronic mental disorders. Archives of Psychiatric Nursing. Feb. 1994;8(1):14-21. Not primary care setting. [pmid: 8203939].
469 Lask B, Bryant-Waugh R, Wright F, et al. Family physician consultation patterns indicate high risk for early-onset anorexia nervosa. International Journal of Eating Disorders. Nov. 2005;38(3):269-72. Not integrated care. [pmid: 16211625].
470 Lave JR, Schulberg HC. Integrating cost-effectiveness analyses within clinical trials of treatment for major depression in primary-care practice Cost-effectiveness of psychotherapy: A guide for practitioners, researchers, and policymakers. New York, NY: Oxford University Press; 1999; 75–84. Not on target, other publication type
471 Lavigne JV, Arend R, Rosenbaum D, et al. Mental health service use among young children receiving pediatric primary care. Journal of the American Academy of Child & Adolescent Psychiatry. Nov. 1998;37(11):1175-83. Not integrated care. [pmid: 9808929].
472 Lawn S, Battersby MW, Pols RG, et al. The mental health expert patient: findings from a pilot study of a generic chronic condition self-management programme for people with mental illness. International Journal of Social Psychiatry. Jan. 2007;53(1):63-74. International. [pmid: 17333952].
473 Lawrie SM, Martin K, McNeill G, et al. General practitioners' attitudes to psychiatric and medical illness. Psychological Medicine. Nov. 1998;28(6):1463-7. Not integrated care. [pmid: 9854287].
474 Lazcano-Ponce E, Alonso P, Ruiz-Moreno JA, et al. Recommendations for cervical cancer screening programs in developing countries. The need for equity and technological development. Salud Publica de Mexico. 2003;45(Suppl 3):S449-62. Not mental health condition. [pmid: 14746039].
475 Lazerson AM. The psychiatrist as teacher in primary care residency training: the first year. International Journal of Psychiatry in Medicine. 1976;7(2):165-78. Medical education. [pmid: 1052089].
476 Ledeboer QC, Van der Velden LA, De Boer MF, et al. Palliative care for head and neck cancer patients in general practice. Acta Oto-Laryngologica. Sep. 2006;126(9):975-80. Not integrated care. [pmid: 16864497].
477 Lee S. Socio-cultural and global health perspectives for the development of future psychiatric diagnostic systems. Psychopathology. Mar–Jun. 2002;35(23):152-7. Not integrated care. [pmid: 12145501].
478 Leech R, van Wyk NC, Uys CJE. The management of infant developmental needs by community nurses. Curationis: South African Journal of Nursing. Jun. 2007;30(2):104-12. Not integrated care.
479 Leeners B, Stiller R, Block E, et al. Effect of childhood sexual abuse on gynecologic care as an adult. Psychosomatics. Sep–Oct. 2007;48(5):385-93. Not integrated care. [pmid: 17878496].
480 Lehman AF, Postrado LT, Roth D, et al. Continuity of care and client outcomes in the Robert Wood Johnson Foundation program on chronic mental illness. Milbank Quarterly. 1994;72(1):105-22. Not integrated care. [pmid: 8164604].
481 Leon AC, Kelsey JE, Pleil A, et al. An evaluation of a computer assisted telephone interview for screening for mental disorders among primary care patients. Journal of Nervous & Mental Disease. May. 1999;187(5):308-11. Not integrated care. [pmid: 10348087].
482 Lessler K. Some considerations pertinent to the health screening of children. The responsibility of pediatrics is much more than biological. Clinical Pediatrics. Nov. 1973;12(11):656-9. Not integrated care. [pmid: 4759508].
483 Lester H, Allan T, Wilson S, et al. A cluster randomised controlled trial of patient-held medical records for people with schizophrenia receiving shared care. British Journal of General Practice. Mar. 2003;53(488):197-203. International. [pmid: 14694695].
484 Lester H, Tritter JQ, Sorohan H. Patients' and health professionals' views on primary care for people with serious mental illness: focus group study. BMJ. May 14. 2005;330(7500):1122. Not integrated care. [pmid: 15843427].
485 Letters P, Stathis S. A mental health and substance abuse service for a youth detention centre. Australasian Psychiatry. Jun. 2004;12(2):126-9. Not primary care setting. [pmid: 15715755].
486 Levine DM, Morlock LL, Mushlin AI, et al. The role of new health practitioners in a prepaid group practice: provider differences in process and outcomes of medical care. Medical Care. Apr. 1976;14(4):326-47. Not integrated care. [pmid: 4680].
487 Levine LA. Diagnosis and treatment of erectile dysfunction. American Journal of Medicine. Dec 18. 2000;109(Suppl 9A):3S-12S. discussion 29S–30S. Not mental health condition. [pmid: 11137497].
488 Lewin LO, Papp KK, Hodder SL, et al. Performance of third-year primary-care-track students in an integrated curriculum at Case Western Reserve. University Academic Medicine. Jan. 1999;74(1 Suppl):S82-9. Medical education. [pmid: 9934315].
489 Lewis G, Sharp D, Bartholomew J, et al. Computerized assessment of common mental disorders in primary care: effect on clinical outcome. Family Practice. Apr. 1996;13(2):120-6. International. [pmid: 8732321].
490 Li PL, Jones I, Richards J. The collection of general practice data for psychiatric service contracts. Journal of Public Health Medicine. Mar. 1994;16(1):87-92. Not primary care setting. [pmid: 8037958].
491 Libby AM, Brent DA, Morrato EH, et al. Decline in treatment of pediatric depression after FDA advisory on risk of suicidality with SSRIs.[see comment]. American Journal of Psychiatry. Jun. 2007;164(6):884-91. Not integrated care. [pmid: 17541047].
492 Lin EH, Katon WJ, Simon GE, et al. Achieving guidelines for the treatment of depression in primary care: is physician education enough?. Medical Care. Aug. 1997;35(8):831-42. Not on target, other publication type. [pmid: 9268255].
493 Lin EH, Katon WJ, Simon GE, et al. Low-intensity treatment of depression in primary care: is it problematic?. General Hospital Psychiatry. Mar–Apr. 2000;22(2):78-83. Not integrated care. [pmid: 10822095].
494 Lin EH, Von Korff M, Katon W, et al. The role of the primary care physician in patients' adherence to antidepressant therapy. Medical Care. Jan. 1995;33(1):67-74. Not integrated care. [pmid: 7823648].
495 Lindgren I, Falk Hogstedt M, Cullberg J. Outpatient vs. comprehensive first-episode psychosis services, a 5-year follow-up of Soteria Nacka. Nordic Journal of Psychiatry. 2006;60(5):405-9. Not integrated care. [pmid: 17050299].
496 Lingler JH, Kaufer DI. Cognitive and motor symptoms in dementia: focus on dementia with Lewy bodies. Journal of the American Academy of Nurse Practitioners. Sep. 2002;14(9):398-404. quiz 5–7. Not mental health condition. [pmid: 12375359].
497 Linszen D, Dingemans P, Lenior M. Early intervention and a five year follow up in young adults with a short duration of untreated psychosis: ethical implications. Schizophrenia Research. Aug 1. 2001;51(1):55-61. Not integrated care. [pmid: 11479066].
498 Lintzeris N, Ritter A, Panjari M, et al. Implementing buprenorphine treatment in community settings in Australia: experiences from the Buprenorphine Implementation Trial. American Journal on Addictions. 2004;13(Suppl 1):S29-41. Not mental health condition. [pmid: 15204674].
499 Lipowski ZJ. Psychiatric consultation: concepts and controversies. American Journal of Psychiatry. May. 1977;134(5):523-8. International. [pmid: 848579].
500 Little P, Dorward M, Warner G, et al. Randomised controlled trial of effect of leaflets to empower patients in consultations in primary care.[see comment]. BMJ. Feb 21. 2004;328(7437):441. International. [pmid: 14966078].
501 Little P, Somerville J, Williamson I, et al. Psychosocial, lifestyle, and health status variables in predicting high attendance among adults. British Journal of General Practice. Dec. 2001;51(473):987-94. Not integrated care. [pmid: 11766871].
502 Little P, Somerville J, Williamson I, et al. Family influences in a cross-sectional survey of higher child attendance. British Journal of General Practice. Dec. 2001;51(473):977-81. Not integrated care. [pmid: 11766870].
503 Liu CY, Chen CY, Cheng AT. Mental illness in a general hospital's family medicine clinic in Taiwan. Psychiatry & Clinical Neurosciences. Oct. 2004;58(5):544-50. International. [pmid: 15482587].
504 Llewellyn-Jones RH, Baikie KA, Smithers H, et al. Multifaceted shared care intervention for late life depression in residential care: randomised controlled trial.[see comment]. BMJ. Sep 11. 1999;319(7211):676-82. Not primary care setting. [pmid: 10480824].
505 Lloyd GG, Doyle Y, Grange C. Medical implications of employee assistance programmes. Occupational Medicine (Oxford). Apr. 1999;49(3):193-5. Not mental health condition.
506 Lloyd J, Davies GP, Harris M. Integration between GPs and hospitals: lessons from a division-hospital program. Australian Health Review. 2000;23(4):134-41. Not primary care setting. [pmid: 11256260].
507 Lloyd-Williams F, Dowrick C, Hillon D, et al. A preliminary communication on whether general dental practitioners have a role in identifying dental patients with mental health problems. British Dental Journal. Dec 8. 2001;191(11):625-9. Not primary care setting. [pmid: 11770949].
508 Lobo A, Perez-Echeverria J, Artal J, et al. Psychiatric morbidity among medical out-patients in Spain: a case for new methods of classification. Journal of Psychosomatic Research. 1988;32(45):355-64. Not integrated care. [pmid: 3236264].
509 Lofvander MB, Engstrom AW, Iglesias E. Do dialogues about concepts of pain reduce immigrant patients' reported spread of pain? A comparison between two consultation methods in primary care. European Journal of Pain: Ejp. May. 2006;10(4):335-41. Not mental health condition. [pmid: 16565030].
510 Logan-Sinclair PA, Davison A. Diagnosing dementia in rural New South Wales. Australian Journal of Rural Health. Jun. 2007;15(3):183-8. Not integrated care. [pmid: 17542791].
511 Lopponen M, Raiha I, Isoaho R, et al. Diagnosing cognitive impairment and dementia in primary health care — a more active approach is needed.[see comment]. Age & Ageing. Nov. 2003;32(6):606-12. Not mental health condition. [pmid: 14600001].
512 Lowe B, Grafe K, Zipfel S, et al. Detecting panic disorder in medical and psychosomatic outpatients: comparative validation of the Hospital Anxiety and Depression Scale, the Patient Health Questionnaire, a screening question, and physicians' diagnosis. Journal of Psychosomatic Research. Dec. 2003;55(6):515-9. Not integrated care. [pmid: 14642981].
513 Luber MP, Meyers BS, Williams-Russo PG, et al. Depression and service utilization in elderly primary care patients. American Journal of Geriatric Psychiatry. 2001;9(2):169-76. Not integrated care. [pmid: 11316621].
514 Lucena RJ, Lesage A. Family physicians and psychiatrists. Qualitative study of physicians' views on collaboration. Canadian Family Physician. May. 2002;48:923-9. International. [pmid: 12053637].
515 Lustig A. Experience with a recently introduced drug information service in an Israeli hospital pharmacy. Pharmacy World & Science. Feb. 1999;21(1):32-4. Not integrated care. [pmid: 10214666].
516 Lydeard S, Jones R. Factors affecting the decision to consult with dyspepsia: comparison of consulters and non-consulters. Journal of the Royal College of General Practitioners. Dec. 1989;39(329):495-8. Not integrated care. [pmid: 2558204].
517 Lyketsos CG, Fishman M, Hutton H, et al. The effectiveness of psychiatric treatment for HIV-infected patients. Psychosomatics. Sep–Oct. 1997;38(5):423-32. not mental health condition. [pmid: 9314711].
518 Lynge I, Munk-Jorgensen P, Pedersen AL, et al. Common mental disorders among patients in primary health care in Greenland. International Journal of Circumpolar Health. 2004;63(Suppl 2):377-83. Not integrated care. [pmid: 15736689].
519 MA IJ, Huijbregts KM, van Marwijk HW, et al. Cost-effectiveness of collaborative care including PST and an antidepressant treatment algorithm for the treatment of major depressive disorder in primary care; a randomised clinical trial. BMC Health Services Research. 2007;7:34. International. [pmid: 17331237].
520 Macdonald W, Bradley S, Bower P, et al. Primary mental health workers in child and adolescent mental health services. Journal of Advanced Nursing. Apr. 2004;46(1):78-87. International. [pmid: 15030444].
521 MacGowan RJ, Swanson NM, Brackbill RM, et al. Retention in methadone maintenance treatment programs, Connecticut and Massachusetts, 1990-1993. Journal of Psychoactive Drugs. Jul–Sep. 1996;28(3):259-65. Not mental health condition. [pmid: 8895111].
522 Magnus M, Schmidt N, Kirkhart K, et al. Association between ancillary services and clinical and behavioral outcomes among HIV-infected women.[see comment]. AIDS Patient Care & Stds. Mar. 2001;15(3):137-45. Not mental health condition. [pmid: 11313026].
523 Magruder-Habib K, Zung WW, Feussner JR, et al. Management of general medical patients with symptoms of depression. General Hospital Psychiatry. May. 1989;11(3):201-7. discussion 16–21. Not on target, other publication type. [pmid: 2721944].
524 Maguire N, Cullen C, O'Sullivan M, et al. What do Dublin GPs expect from a psychiatric referral?. Irish Medical Journal. Nov–Dec. 1995;88(6):215-6. Not integrated care. [pmid: 8575922].
525 Maheux B, Haley N, Rivard M, et al. Do physicians assess lifestyle health risks during general medical examinations? A survey of general practitioners and obstetrician-gynecologists in Quebec.[see comment]. CMAJ Canadian Medical Association Journal. Jun 29. 1999;160(13):1830-4. Not integrated care. [pmid: 10405667].
526 Malhotra K, Schwartz T, Hameed U. Presence of suicidality as a prognostic indicator. Journal of Postgraduate Medicine. Jul–Sep. 2004;50(3):185-7. discussion 7–8. Not integrated care. [pmid: 15377802].
527 Malla A, Norman R, Scholten D, et al. A community intervention for early identification of first episode psychosis: impact on duration of untreated psychosis (DUP) and patient characteristics. Social Psychiatry & Psychiatric Epidemiology. May. 2005;40(5):337-44. International. [pmid: 15902403].
528 Malla AK, Norman RM, McLean TS, et al. An integrated medical and psychosocial treatment program for psychotic disorders: patient characteristics and outcome. Canadian Journal of Psychiatry - Revue Canadienne de Psychiatrie. Sep. 1998;43(7):698-705. International. [pmid: 9773219].
529 Manderscheid RW, Masi D, Rossignol CR, et al. The integration of physical health and behavioral health services: three university case examples. Archives of Psychiatric Nursing. Jun. 2007;21(3):141-9. Not included study design. [pmid: 17556107].
530 Mann AH, Blanchard M, Waterreus A. Depression in older people. Some criteria for effective treatment. Encephale. Aug. 1993;19(Spec No 3):445-50. International. [pmid: 8299543].
531 Mann JJ, Apter A, Bertolote J, et al. Suicide prevention strategies: a systematic review.[see comment]. JAMA. Oct 26. 2005;294(16):2064-74. Not integrated care. [pmid: 16249421].
532 Mannino FV, Shore MF. Consultation research in mental health and related fields; a critical review of the literature. Public Health Monograph. 1970;79:1-55. Not on target, other publication type. [pmid: 4935576].
533 Marcantonio ER, Flacker JM, Wright RJ, et al. Reducing delirium after hip fracture: a randomized trial.[see comment]. Journal of the American Geriatrics Society. May. 2001;49(5):516-22. Not mental health condition. [pmid: 11380742].
534 Markson LJ, Kern DC, Annas GJ, et al. Physician assessment of patient competence.[see comment]. Journal of the American Geriatrics Society. Oct. 1994;42(10):1074-80. Not integrated care. [pmid: 7930332].
535 Marshall M, Lockwood A, Gath D. Social services case-management for long-term mental disorders: a randomised controlled trial.[see comment]. Lancet. Feb 18. 1995;345(8947):409-12. Not primary care setting. [pmid: 7853949].
536 Martinez-Ramirez HR, Jalomo-Martinez B, Cortes-Sanabria L, et al. Renal function preservation in type 2 diabetes mellitus patients with early nephropathy: a comparative prospective cohort study between primary health care doctors and a nephrologist. American Journal of Kidney Diseases. Jan. 2006;47(1):78-87. Not mental health condition. [pmid: 16377388].
537 Maruish ME, Bershadsky B, Goldstein L. Reliability and validity of the SA-45: further evidence from a primary care setting. Assessment. Dec. 1998;5(4):407-19. Not on target, other publication type. [pmid: 9835664].
538 Matalon A, Nahmani T, Rabin S, et al. A short-term intervention in a multidisciplinary referral clinic for primary care frequent attenders: description of the model, patient characteristics and their use of medical resources. Family Practice. Jun. 2002;19(3):251-6. International. [pmid: 11978715].
539 Matsumura G, Callister LC, Palmer S, et al. Staff nurse perceptions of the contributions of students to clinical agencies. Nursing Education Perspectives. Nov–Dec. 2004;25(6):297-303. Not integrated care. [pmid: 15675378].
540 Mauksch LB, Katon WJ, Russo J, et al. The content of a low-income, uninsured primary care population: including the patient agenda. Journal of the American Board of Family Practice. Jul–Aug. 2003;16(4):278-89. Not integrated care. [pmid: 12949028].
541 May C, Rapley T, Kaner E. Clinical reasoning, clinical trials and risky drinkers in everyday primary care: A qualitative study of British general practitioners. Addiction Research & Theory. Aug. 2006;14(4):387-97. Not integrated care.
542 Mayou RA, Bass CM, Bryant BM. Management of non-cardiac chest pain: from research to clinical practice. Heart. Apr. 1999;81(4):387-92. Not mental health condition. [pmid: 10092565].
543 McArt EW, Shulman DA, Gajary E. Developing an educational workshop on teen depression and suicide: a proactive community intervention. Child Welfare. Nov–Dec. 1999;78(6):793-806. Not integrated care. [pmid: 10627989].
544 McCann TV, Baker H. Models of mental health nurse-general practitioner liaison: promoting continuity of care. Journal of Advanced Nursing. Mar. 2003;41(5):471-9. International. [pmid: 12603572].
545 McCarthy JF, Bambauer KZ, Austin K, et al. Treatment for new episodes of depression. Psychiatric Services. Aug. 2007;58(8):1035. Not included study design. [pmid: 17664511].
546 McClelland CQ, Staples WI, Weisberg I, et al. The practitioner's role in behavioral pediatrics. Journal of Pediatrics. Feb. 1973;82(2):325-31. Not integrated care. [pmid: 4684380].
547 McCombie SL, Bassuk E, Savitz R, et al. Development of a medical center rape crisis intervention program. American Journal of Psychiatry. Apr. 1976;133(4):418-21. Not mental health condition. [pmid: 1267041].
548 McConaghy JR, Smith SR. Outpatient treatment of systolic heart failure.[see comment][summary for patients in Am Fam Physician. 2004 Dec 1;70(11):2171–2; PMID: 15606065]. American Family Physician. Dec 1. 2004;70(11):2157-64. Not mental health condition. [pmid: 15606064].
549 McCray J, Carter S. A study to determine the qualities of a learning disability practitioner. British Journal of Nursing. Nov 28–Dec 11. 2002;11(21):1380-5. Not mental health condition. [pmid: 12514472].
550 McCrone P, Fitzpatrick NK, Mathieson E, et al. Economic implications of shared care arrangements. A primary care based study of patients in an inner city sample. Social Psychiatry & Psychiatric Epidemiology. Jul. 2004;39(7):553-9. International. [pmid: 15243693].
551 McCullough AR, Barada JH, Fawzy A, et al. Achieving treatment optimization with sildenafil citrate (Viagra) in patients with erectile dysfunction. Urology. Sep. 2002;60(2 Suppl 2):28-38. Not mental health condition. [pmid: 12414331].
552 McCusker J, Boulenger JP, Bellavance F, et al. Outcomes in a referral cohort of patients with anxiety disorders. Journal of Nervous & Mental Disease. Jan. 2000;188(1):3-12. Not integrated care. [pmid: 10665454].
553 McCusker J, Jacobs P, Dendukuri N, et al. Cost-effectiveness of a brief two-stage emergency department intervention for high-risk elders: results of a quasi-randomized controlled trial. Annals of Emergency Medicine. Jan. 2003;41(1):45-56. Not primary care setting. [pmid: 12514682].
554 McCusker J, Verdon J, Tousignant P, et al. Rapid emergency department intervention for older people reduces risk of functional decline: results of a multicenter randomized trial.[see comment]. Journal of the American Geriatrics Society. Oct. 2001;49(10):1272-81. Not primary care setting. [pmid: 11890484].
555 McDonald IG, Daly J, Jelinek VM, et al. Opening Pandora's box: the unpredictability of reassurance by a normal test result. BMJ. Aug 10. 1996;313(7053):329-32. Not integrated care. [pmid: 8760739].
556 McEvoy P, Richards D. Gatekeeping access to community mental health teams: a qualitative study. International Journal of Nursing Studies. Mar. 2007;44(3):387-95. International. [pmid: 16843468].
557 McGibben L, Ballard C. Child psychiatry liaison services.[comment]. British Journal of Psychiatry. Apr. 1991;158:573. Not on target, other publication type. [pmid: 2054577].
558 McGorry PD, Edwards J, Mihalopoulos C, et al. EPPIC: an evolving system of early detection and optimal management. Schizophrenia Bulletin. 1996;22(2):305-26. Not primary care setting. [pmid: 8782288].
559 McHugh F, Lindsay GM, Hanlon P, et al. Nurse led shared care for patients on the waiting list for coronary artery bypass surgery: a randomised controlled trial.[see comment]. Heart. Sep. 2001;86(3):317-23. International. [pmid: 11514487].
560 McKay JR, Lynch KG, Shepard DS, et al. The effectiveness of telephone-based continuing care for alcohol and cocaine dependence: 24-month outcomes. Archives of General Psychiatry. Feb. 2005;62(2):199-207. Not integrated care. [pmid: 15699297].
561 McKay K. Evaluating model programs to support dissemination. An evaluation of strengthening the developmental surveillance and referral practices of child health providers. Journal of Developmental & Behavioral Pediatrics. Feb. 2006;27(1 Suppl):S26-9. discussion S34–7. Not mental health condition. [pmid: 16715788].
562 McKeown A, Matheson C, Bond C. A qualitative study of GPs' attitudes to drug misusers and drug misuse services in primary care. Family Practice. Apr. 2003;20(2):120-5. Not integrated care. [pmid: 12651783].
563 McLean M, Armstrong D. Eliciting patients' concerns: a randomised controlled trial of different approaches by the doctor.[see comment]. British Journal of General Practice. Sep. 2004;54(506):663-6. Not integrated care. [pmid: 15353051].
564 McMahon JD, Macfarlane A, Avalos GE, et al. A survey of asylum seekers' general practice service utilisation and morbidity patterns. Irish Medical Journal. May. 2007;100(5):461-4. Not integrated care. [pmid: 17727121].
565 McVey LJ, Becker PM, Saltz CC, et al. Effect of a geriatric consultation team on functional status of elderly hospitalized patients. A randomized, controlled clinical trial.[see comment]. Annals of Internal Medicine. Jan 1. 1989;110(1):79-84. Not primary care setting. [pmid: 2642284].
566 Meadows G. Evaluating consultation-liaison in general practice.[see comment][comment]. Australian & New Zealand Journal of Psychiatry. Oct. 1998;32(5):728-30. International. [pmid: 9805598].
567 Medow MA, Wilt TJ, Dysken S, et al. Effect of written and computerized decision support aids for the U.S. Agency for Health Care Policy and Research depression guidelines on the evaluation of hypothetical clinical scenarios. Medical Decision Making. Sep–Oct. 2001;21(5):344-56. Not integrated care. [pmid: 11575484].
568 Meeuwesen L, Huyse FJ, Koopmans GT, et al. Supervised integrated screening of low-back pain patients by a neurologist. A randomized clinical trial. General Hospital Psychiatry. Nov. 1996;18(6):385-94. International. [pmid: 8937904].
569 Meeuwesen L, Huyse FJ, Meiland FJ, et al. Psychiatric consultations in medical outpatients with abdominal pain: patient and physician effects. International Journal of Psychiatry in Medicine. 1994;24(4):339-56. International. [pmid: 7737789].
570 Melrose S, Shapiro B. Students' perceptions of their psychiatric mental health clinical nursing experience: a personal construct theory exploration. Journal of Advanced Nursing. Dec. 1999;30(6):1451-8. Not integrated care. [pmid: 10583657].
571 Menahem S, Roth D, Haramati S. Psychiatric collaboration in a paediatric department. Australian & New Zealand Journal of Psychiatry. Apr. 1997;31(2):214-8. International. [pmid: 9140628].
572 Mertens JR, Weisner CM, Ray GT. Readmission among chemical dependency patients in private, outpatient treatment: patterns, correlates and role in long-term outcome. Journal of Studies on Alcohol. Nov. 2005;66(6):842-7. Not integrated care. [pmid: 16459946].
573 Meyer JM. Strategies for the long-term treatment of schizophrenia: real-world lessons from the CATIE trial. Journal of Clinical Psychiatry. 2007;68(Suppl 1):28-33. Not on target, other publication type. [pmid: 17286525].
574 Mezzina R, Vidoni D. Beyond the mental hospital: crisis intervention and continuity of care in Trieste. International Journal of Social Psychiatry. 1995;41(1):1-20. Not primary care setting. [pmid: 7622336].
575 Mickenautsch S, Rudolph MJ. Undergraduate training in the atraumatic restorative treatment (ART) approach—an activity report. SADJ. Sep. 2002;57(9):355-7. Not mental health condition. [pmid: 12494711].
576 Miles MS, Holditch-Davis D, Eron J, et al. An HIV self-care symptom management intervention for African American mothers. Nursing Research. Nov–Dec. 2003;52(6):350-60. Not mental health condition. [pmid: 14639081].
577 Milgrom J, Ericksen J, Negri L, et al. Screening for postnatal depression in routine primary care: properties of the Edinburgh Postnatal Depression Scale in an Australian sample. Australian & New Zealand Journal of Psychiatry. Sep. 2005;39(9):833-9. Not integrated care. [pmid: 16168042].
578 Miller AR, Lalonde CE, McGrail KM, et al. Prescription of methylphenidate to children and youth, 1990-1996.[see comment]. CMAJ Canadian Medical Association Journal. Nov 27. 2001;165(11):1489-94. Not primary care setting. [pmid: 11762572].
579 Miller MJ, McCrone S. Detection of depression in primary care. Military Medicine. Feb. 2005;170(2):158-63. Not integrated care. [pmid: 15782839].
580 Miller NE, Magruder KM. Cost-effectiveness of psychotherapy: A guide for practitioners, researchers, and policymakers New York, NY: Oxford University Press; 1999. Not on target, other publication type
581 Miller SM, Brody DS, Summerton J. Styles of coping with threat: implications for health. Journal of Personality & Social Psychology. Jan. 1988;54(1):142-8. Not integrated care. [pmid: 3346803].
582 Miller V. Forum for Collaborative HIVRWPaSCM. Buprenorphine and HIV primary care: report of a forum for collaborative HIV research workshop. Clinical Infectious Diseases. Dec 15. 2006;43(Suppl 4):S254-7. Not mental health condition. [pmid: 17109312].
583 Mine K, Kanazawa F, Hosoi M, et al. Treating nonulcer dyspepsia considering both functional disorders of the digestive system and psychiatric conditions. Digestive Diseases & Sciences. Jun. 1998;43(6):1241-7. Not mental health condition. [pmid: 9635614].
584 Miranda J, Azocar F, Organista KC, et al. Treatment of depression among impoverished primary care patients from ethnic minority groups. Psychiatric Services. Feb. 2003;54(2):219-25. Not integrated care. [pmid: 12556604].
585 Mitchell G, Del Mar C, Francis D. Does primary medical practitioner involvement with a specialist team improve patient outcomes? A systematic review. British Journal of General Practice. Nov. 2002;52(484):934-9. Not on target, other publication type. [pmid: 12434964].
586 Mitchell J, Howell C, Turnbull D, et al. Computer-assisted group therapy for the treatment of depression and anxiety in general practice. Primary Care Mental Health. 2005;3(1):27-39. International.
587 Mitty J, Macleod C, Loewenthal H, et al. An integrated program of buprenorphine in the primary care setting for HIV(+) persons in Rhode Island. Medicine & Health, Rhode Island. May. 2007;90(5):145-7. not mental health condition.
588 Moffatt S, White M, Stacy R, et al. The impact of welfare advice in primary care: a qualitative study. Critical Public Health. Sep. 2004;14(3):295-309. Not integrated care.
589 Morgan CD, Marsh C. Bulimia nervosa in an elderly male: a case report. International Journal of Eating Disorders. Mar. 2006;39(2):170-1. Not integrated care. [pmid: 16252279].
590 Morgan DG. ‘Please see and advise’: a qualitative study of patients' experiences of psychiatric outpatient care. Social Psychiatry & Psychiatric Epidemiology. Aug. 1999;34(8):442-50. Not integrated care. [pmid: 10501715].
591 Morgan M, Jenkins L, Ridsdale L. Patient pressure for referral for headache: a qualitative study of GPs' referral behaviour. British Journal of General Practice. Jan. 2007;57(534):29-35. Not integrated care. [pmid: 17244421].
592 Morgenstern J, Blanchard KA, McCrady BS, et al. Effectiveness of intensive case management for substance-dependent women receiving temporary assistance for needy families. American Journal of Public Health. Nov. 2006;96(11):2016-23. Not primary care setting. [pmid: 17018819].
593 Morriss R, Gask L, Ronalds C, et al. Cost-effectiveness of a new treatment for somatized mental disorder taught to GPs. Family Practice. Apr. 1998;15(2):119-25. International. [pmid: 9613478].
594 Morrissey JP, Calloway MO, Thakur N, et al. Integration of service systems for homeless persons with serious mental illness through the ACCESS program. Access to Community Care and Effective Services and Supports.[see comment]. Psychiatric Services. Aug. 2002;53(8):949-57. Not primary care setting. [pmid: 12161668].
595 Morse GA, Calsyn RJ, Allen G, et al. Experimental comparison of the effects of three treatment programs for homeless mentally ill people. Hospital & Community Psychiatry. Oct. 1992;43(10):1005-10. Not primary care setting. [pmid: 1398563].
596 Mountford L. Using an assessment tool for mental health team referrals.[see comment]. Nursing Times. Jun 1–7. 2004;100(22):38-40. International. [pmid: 15195543].
597 Munsch S, Biedert E, Keller U. Evaluation of a lifestyle change programme for the treatment of obesity in general practice. Swiss Medical Weekly. Mar 8. 2003;133(910):148-54. Not mental health condition. [pmid: 12707842].
598 Murchie P, Campbell NC, Ritchie LD, et al. Effects of secondary prevention clinics on health status in patients with coronary heart disease: 4 year follow-up of a randomized trial in primary care. Family Practice. Oct. 2004;21(5):567-74. Not mental health condition. [pmid: 15367480].
599 Murray J, Corney R. Not a medical problem? An intensive study of the attitudes and illness behaviour of low attenders with psychosocial difficulties. Social Psychiatry & Psychiatric Epidemiology. May. 1990;25(3):159-64. Not integrated care. [pmid: 2349503].
600 Nandy S, Chalmers-Watson C, Gantley M, et al. Referral for minor mental illness: a qualitative study. British Journal of General Practice. Jun. 2001;51(467):461-5. Not integrated care. [pmid: 11407051].
601 Navon M, Nelson D, Pagano M, et al. Use of the pediatric symptom checklist in strategies to improve preventive behavioral health care. Psychiatric Services. Jun. 2001;52(6):800-4. Not on target, other publication type. [pmid: 11376228].
602 Naylor MD, Brooten D, Campbell R, et al. Comprehensive discharge planning and home follow-up of hospitalized elders: a randomized clinical trial.[see comment]. JAMA. Feb 17. 1999;281(7):613-20. Not primary care setting. [pmid: 10029122].
603 Nazareth I, King M, Haines A, et al. Care of schizophrenia in general practice. BMJ. Oct 9. 1993;307(6909):910. International. [pmid: 8241855].
604 Nazareth I, Yardley L, Owen N, et al. Outcome of symptoms of dizziness in a general practice community sample. Family Practice. Dec. 1999;16(6):616-8. Not integrated care. [pmid: 10625139].
605 Neal RD, Colledge M. The effect of the full moon on general practice consultation rates. Family Practice. Dec. 2000;17(6):472-4. Not integrated care. [pmid: 11120717].
606 Nekolaichuk CL, Maguire TO, Suarez-Almazor M, et al. Assessing the reliability of patient, nurse, and family caregiver symptom ratings in hospitalized advanced cancer patients. Journal of Clinical Oncology. Nov. 1999;17(11):3621-30. Not primary care setting. [pmid: 10550162].
607 Nettleton S. ‘I just want permission to be ill’: towards a sociology of medically unexplained symptoms. Social Science & Medicine. Mar. 2006;62(5):1167-78. Not primary care setting. [pmid: 16135395].
608 Neubuerger OW, Miller SI, Schmitz RE, et al. Replicable abstinence rates in an alcoholism treatment program. JAMA. Aug 27. 1982;248(8):960-3. Not integrated care. [pmid: 7097964].
609 Newacheck PW, Hughes DC, Halfon N, et al. Social HMOs and other capitated arrangements for children with special health care needs. Maternal & Child Health Journal. Jun. 1997;1(2):111-9. Not integrated care. [pmid: 10728233].
610 Newcomer R, Yordi C, DuNah R, et al. Effects of the Medicare Alzheimer's Disease Demonstration on caregiver burden and depression.[see comment]. Health Services Research. Aug. 1999;34(3):669-89. Not primary care setting. [pmid: 10445897].
611 Newell R, Gournay K. British nurses in behavioural psychotherapy: a 20-year follow-up. Journal of Advanced Nursing. Jul. 1994;20(1):53-60. Not integrated care. [pmid: 7930128].
612 Newens AJ, Forster DP, Kay DW. Referral patterns and diagnosis in presenile Alzheimer's disease: implications for general practice. British Journal of General Practice. Sep. 1994;44(386):405-7. Not mental health condition. [pmid: 8790653].
613 No authorship i. Link Between Depression and Heart Disease Found Drug Benefit Trends 2005 Apr; 17(4):182. International
614 Nordentoft M, Thorup A, Petersen L, et al. Transition rates from schizotypal disorder to psychotic disorder for first-contact patients included in the OPUS trial. A randomized clinical trial of integrated treatment and standard treatment. Schizophrenia Research. Mar. 2006;83(1):29-40. International. [pmid: 16504481].
615 Norton PG, Nelson W, Rudner HL, et al. Relative costs of specialist services in a family practice population. CMAJ Canadian Medical Association Journal. Oct 15. 1985;133(8):759-61. Not primary care setting. [pmid: 4042059].
616 Nuttbrock L, McQuistion H, Rosenblum A, et al. Broadening perspectives on mobile medical outreach to homeless people.[erratum appears in J Health Care Poor Underserved. 2003 May;14(2):290]. Journal of Health Care for the Poor & Underserved. Feb. 2003;14(1):5-16. Not primary care setting. [pmid: 12613064].
617 Odejide AO, Morakinyo JJ, Oshiname FO, et al. Integrating mental health into primary health care in Nigeria: management of depression in a local government (district) area as a paradigm. Seishin Shinkeigaku Zasshi - Psychiatria et Neurologia Japonica. 2002;104(10):802-9. International. [pmid: 12607921].
618 O'Donnell JC, Toseland RW. Does geriatric evaluation and management improve the health behavior of older veterans in psychological distress?. Journal of Aging & Health. Nov. 1997;9(4):473-97. Not on target, other publication type. [pmid: 10182389].
619 Ogg EC, Millar HR, Pusztai EE, et al. General practice consultation patterns preceding diagnosis of eating disorders. International Journal of Eating Disorders. Jul. 1997;22(1):89-93. Not integrated care. [pmid: 9140741].
620 Ogur B, Hirsh D, Krupat E, et al. The Harvard Medical School-Cambridge integrated clerkship: an innovative model of clinical education. Academic Medicine. Apr. 2007;82(4):397-404. Not integrated care. [pmid: 17414198].
621 Oiesvold T, Sandlund M, Hansson L, et al. Factors associated with referral to psychiatric care by general practitioners compared with self-referrals. Psychological Medicine. Mar. 1998;28(2):427-36. Not integrated care. [pmid: 9572099].
622 Oishi SM, Shoai R, Katon W, et al. Impacting late life depression: Integrating a depression intervention into primary care. Psychiatric Quarterly. Spr. 2003;74(1):75-89. International. [pmid: 12602790].
623 Olbrisch ME, Levenson JL. Psychosocial evaluation of heart transplant candidates: an international survey of process, criteria, and outcomes. Journal of Heart Lung Transplantation. Nov–Dec. 1991;10(6):948-55. Not mental health condition. [pmid: 1756161].
624 olde Hartman TC, Lucassen PL, van de Lisdonk EH, et al. Chronic functional somatic symptoms: a single syndrome?. British Journal of General Practice. Dec. 2004;54(509):922-7. International. [pmid: 15588538].
625 Olfson M, Mechanic D, Boyer CA, et al. Linking inpatients with schizophrenia to outpatient care. Psychiatric Services. Jul. 1998;49(7):911-7. Not primary care setting. [pmid: 9661225].
626 Olness K, Gardner GG. Some guidelines for uses of hypnotherapy in pediatrics. Pediatrics. Aug. 1978;62(2):228-33. Not mental health condition. [pmid: 80783].
627 Olson AL, Dietrich AJ, Prazar G, et al. Brief maternal depression screening at well-child visits. Pediatrics. Jul. 2006;118(1):207-16. Not integrated care. [pmid: 16818567].
628 Olson AL, Dietrich AJ, Prazar G, et al. Two approaches to maternal depression screening during well child visits. Journal of Developmental & Behavioral Pediatrics. Jun. 2005;26(3):169-76. Not integrated care. [pmid: 15956865].
629 O'Malley PG. Collaborative care for depression in patients with diabetes increased depression-free days and had economic benefit ACP. Journal Club. May–Jun. 2007;146(3):78. Not on target, other publication type.
630 O'Malley PG, Jackson JL, Kroenke K, et al. The value of screening for psychiatric disorders in rheumatology referrals. Archives of Internal Medicine. Nov 23. 1998;158(21):2357-62. Not primary care setting. [pmid: 9827787].
631 O'Reilly R, Bishop J, Maddox K, et al. Is telepsychiatry equivalent to face-to-face psychiatry? Results from a randomized controlled equivalence trial. Psychiatric Services. Jun. 2007;58(6):836-43. Not integrated care. [pmid: 17535945].
632 Ormel J, Van Den Brink W, Koeter MW, et al. Recognition, management and outcome of psychological disorders in primary care: a naturalistic follow-up study. Psychological Medicine. Nov. 1990;20(4):909-23. International. [pmid: 2284397].
633 Oslin DW. Late-life alcoholism: issues relevant to the geriatric psychiatrist. American Journal of Geriatric Psychiatry. Nov–Dec. 2004;12(6):571-83. Not on target, other publication type. [pmid: 15545325].
634 Oslin DW, Sayers S, Ross J, et al. Disease management for depression and at-risk drinking via telephone in an older population of veterans. Psychosomatic Medicine. Nov–Dec. 2003;65(6):931-7. Not primary care setting. [pmid: 14645769].
635 Osuch E, Engel CC Jr. Research on the treatment of trauma spectrum responses: the role of the optimal healing environment and neurobiology. Journal of Alternative & Complementary Medicine. 2004;10(Suppl 1):S211-21. Not mental health condition. [pmid: 15630838].
636 O'Toole TP, Strain EC, Wand G, et al. Outpatient treatment entry and health care utilization after a combined medical/substance abuse intervention for hospitalized medical patients. Journal of General Internal Medicine. May. 2002;17(5):334-40. Not primary care setting. [pmid: 12047729].
637 Oud MJ, Schuling J, Slooff CJ, et al. How do General Practitioners experience providing care for their psychotic patients?. BMC Family Practice. 2007;8:37. Not integrated care. [pmid: 17598879].
638 Owen A, Winkler R. General practitioners and psychosocial problems: An evaluation using pseudopatients. Medical Journal of Australia. Sep 14. 1974;2(11):393-8. International. [pmid: 4431336].
639 Owens C, Lambert H, Donovan J, et al. A qualitative study of help seeking and primary care consultation prior to suicide. British Journal of General Practice. Jul. 2005;55(516):503-9. Not integrated care. [pmid: 16004734].
640 Oxman TE. Collaborative care may improve depression management in older adults. Evidence-Based Mental Health. Aug. 2003;6(3):86. International. [pmid: 12893797].
641 Oxman TE, Dietrich AJ, Schulberg HC. The depression care manager and mental health specialist as collaborators within primary care. American Journal of Geriatric Psychiatry. Sep–Oct. 2003;11(5):507-16. Not on target, other publication type. [pmid: 14506084].
642 Oxman TE, Schulberg HC, Greenberg RL, et al. A fidelity measure for integrated management of depression in primary care. Medical Care. Nov. 2006;44(11):1030-7. Not on target, other publication type. [pmid: 17063135].
643 Palepu A, Cheng DM, Kim T, et al. Substance abuse treatment and receipt of liver specialty care among persons coinfected with HIV/HCV who have alcohol problems. Journal of Substance Abuse Treatment. Dec. 2006;31(4):411-7. Not integrated care. [pmid: 17084795].
644 Palepu A, Tyndall MW, Leon H, et al. Hospital utilization and costs in a cohort of injection drug users.[see comment]. CMAJ Canadian Medical Association Journal. Aug 21. 2001;165(4):415-20. Not mental health condition. [pmid: 11531049].
645 Palmer KT, Calnan M, Wainwright D, et al. Upper limb pain in primary care: health beliefs, somatic distress, consulting and patient satisfaction. Family Practice. Dec. 2006;23(6):609-17. International. [pmid: 17035285].
646 Parameshvara Deva M. Malaysia mental health country profile. International Review of Psychiatry. Feb–May. 2004;16(12):167-76. Not mental health condition. [pmid: 15276949].
647 Parisi MA, Ramsdell LA, Burns MW, et al. A Gender Assessment Team: experience with 250 patients over a period of 25 years Genetics in. Medicine. Jun. 2007;9(6):348-57. not primary care setting.
648 Parker C, Hippisley-Cox J, Coupland C, et al. Rectal and postmenopausal bleeding: consultation and referral of patients with and without severe mental health problems. British Journal of General Practice. May. 2007;57(538):371-6. Not integrated care. [pmid: 17504587].
649 Parker T, May PA, Maviglia MA, et al. PRIME-MD: its utility in detecting mental disorders in American Indians. International Journal of Psychiatry in Medicine. 1997;27(2):107-28. Not integrated care. [pmid: 9565718].
650 Parr JM, Kavanagh DJ, Young RM, et al. Views of general practitioners and benzodiazepine users on benzodiazepines: a qualitative analysis. Social Science & Medicine. Mar. 2006;62(5):1237-49. Not mental health condition. [pmid: 16143440].
651 Parson C. Managed care. The effect of case management on state psychiatric clients. Journal of Psychosocial Nursing & Mental Health Services. Oct. 1999;37(10):16-21. Not primary care setting. [pmid: 10529959].
652 Partridge L, Gems D. Beyond the evolutionary theory of ageing, from functional genomics to evo-gero. Trends in Ecology & Evolution. Jun. 2006;21(6):334-40. Not integrated care. [pmid: 16769434].
653 Passamonti M, Pigni M, Fraticelli C, et al. Somatic symptoms and depression in general practice in Italy. European Journal of General Practice. Jun. 2003;9(2):66-7. Not integrated care. [pmid: 14611019].
654 Passchier J, de Boo M, Quaak HZ, et al. Health-related quality of life of chronic headache patients is predicted by the emotional component of their pain. Headache. Oct. 1996;36(9):556-60. Not mental health condition. [pmid: 8916564].
655 Passik SD, Whitcomb LA, Kirsh KL, et al. A pilot study of oncology staff perceptions of palliative care and psycho-oncology services in rural and community settings in Indiana. Journal of Rural Health. 2002;18(1):31-4. Not primary care setting. [pmid: 12043753].
656 Patel V. Spiritual distress: an indigenous model of nonpsychotic mental illness in primary care in Harare, Zimbabwe. Acta Psychiatrica Scandinavica. Aug. 1995;92(2):103-7. Not integrated care. [pmid: 7572254].
657 Patel V, Araya R, Chatterjee S, et al. Treatment and prevention of mental disorders in low-income and middle-income countries. Lancet. Sep 15. 2007;370(9591):991-1005. Not on target, other publication type. [pmid: 17804058].
658 Pearson B, Katz SE, Soucie V, et al. Evidence-based care for depression in Maine: dissemination of the Kaiser Permanente Nurse Telecare Program. Psychiatric Quarterly. 2003;74(1):91-102. Not included study design. [pmid: 12602791].
659 Peindl KS, Wisner KL, Hanusa BH. Identifying depression in the first postpartum year: guidelines for office-based screening and referral. Journal of Affective Disorders. May. 2004;80(1):37-44. Not integrated care. [pmid: 15094256].
660 Peters T, Somerset M, Baxter K, et al. Anxiety among women with mild dyskaryosis: a randomized trial of an educational intervention. British Journal of General Practice. May. 1999;49(442):348-52. Not mental health condition. [pmid: 10736883].
661 Petersen I. Training for transformation: reorientating primary health care nurses for the provision of mental health care in South Africa. Journal of Advanced Nursing. Oct. 1999;30(4):907-15. International. [pmid: 10520104].
662 Peters-Klimm F, Muller-Tasch T, Schellberg D, et al. Rationale, design and conduct of a randomised controlled trial evaluating a primary care-based complex intervention to improve the quality of life of heart failure patients: HICMan (Heidelberg Integrated Case Management). BMC Cardiovascular Disorders. 2007;7:25. Not integrated care. [pmid: 17716364].
663 Pfaff JJ, Almeida OP. Identifying suicidal ideation among older adults in a general practice setting. Journal of Affective Disorders. Nov 15. 2004;83(1):73-7. Not integrated care. [pmid: 15546648].
664 Pfefferle SG. Pediatrician screening and coordination of care for children with mental illnesses Pfefferle, Susan G: Brandeis U, The Heller School For Social Policy And Management, US; 2006. Not integrated care
665 Phillips D, Brooks F. Women users' views on the role and value of the practice nurse. Health and Social Care in the Community. May. 1998;6(3):164-71. International. [pmid: 11560588].
666 Phillips GA, Brophy DS, Weiland TJ, et al. The effect of multidisciplinary case management on selected outcomes for frequent attenders at an emergency department.[see comment]. Medical Journal of Australia. Jun 19. 2006;184(12):602-6. Not primary care setting. [pmid: 16803437].
667 Phillips N, Dennerstein L, Farish S. Progress and evaluation of a consultation-liaison psychiatry service to an obstetric-gynaecology hospital.[see comment]. Australian & New Zealand Journal of Psychiatry. Feb. 1996;30(1):82-9. Not primary care setting. [pmid: 8724330].
668 Philp EB, Parker P, Rubin N, et al. The difficult patient: creation of a curriculum by third-year family practice residents.[see comment]. Family Medicine. Sep. 1996;28(8):553-8. e. [pmid: 8884251].
669 Phongsavan P, Ward JE, Oldenburg BF, et al. Mental health care practices and educational needs of general practitioners. Medical Journal of Australia. Feb 6. 1995;162(3):139-42. Not integrated care. [pmid: 7854226].
670 Pierce D, Wilson I. Psychiatric comorbidity in general practice.[see comment][comment]. Australian Family Physician. Apr. 2004;33(4):217-20. Not integrated care. [pmid: 15129464].
671 Pieters G. Collaborative care led to greater recovery, improvement, and adherence than usual care at 12 months in panic disorder. Evidence-Based Mental Health. May. 2002;5(2):49. International. [pmid: 12026898].
672 Piette JD, Weinberger M, McPhee SJ. The effect of automated calls with telephone nurse follow-up on patient-centered outcomes of diabetes care: a randomized, controlled trial. Medical Care. Feb. 2000;38(2):218-30. Not on target, other publication type. [pmid: 10659695].
673 Pignone MP, Gaynes BN, Rushton JL, et al. Screening for depression in adults: a summary of the evidence for the U.S. Preventive Services Task Force.[see comment][summary for patients in Ann Intern Med. 2002 May 21;136(10):I56; PMID: 12020161]. Annals of Internal Medicine. May 21. 2002;136(10):765-76. Not integrated care. [pmid: 12020146].
674 Pimlott NJ. Pharmacologic or behavioural therapy for elderly people's insomnia. Which is better?. Canadian Family Physician. Jul. 2000;46:1430-2. Not mental health condition. [pmid: 10925757].
675 Planavsky LA, Mion LC, Litaker DG, et al. Ending a nurse practitioner-patient relationship: uncovering patients' perceptions. Journal of the American Academy of Nurse Practitioners. Sep. 2001;13(9):428-32. Not integrated care. [pmid: 11930855].
676 Platz C, Umbricht DS, Cattapan-Ludewig K, et al. Help-seeking pathways in early psychosis. Social Psychiatry & Psychiatric Epidemiology. Dec. 2006;41(12):967-74. Not integrated care. [pmid: 17036265].
677 Plummer SE, Ritter SA, Leach RE, et al. A controlled comparison of the ability of practice nurses to detect psychological distress in patients who attend their clinics. Journal of Psychiatric & Mental Health Nursing. Jun. 1997;4(3):221-2. Not integrated care. [pmid: 9325803].
678 Pollack MH, Allgulander C, Bandelow B, et al. WCA recommendations for the long-term treatment of panic disorder. Cns Spectrums. Aug. 2003;8(8 Suppl 1):17-30. Not on target, other publication type. [pmid: 14767395].
679 Pollock K, Grime J. Patients' perceptions of entitlement to time in general practice consultations for depression: qualitative study. BMJ. Sep 28. 2002;325(7366):687. International. [pmid: 12351362].
680 Popkin MK, Lurie N, Manning W, et al. Changes in the process of care for Medicaid patients with schizophrenia in Utah's Prepaid Mental Health Plan.[see comment]. Psychiatric Services. Apr. 1998;49(4):518-23. Not integrated care. [pmid: 9550244].
681 Porzio G, Ricevuto E, Aielli F, et al. The Supportive Care Task Force at the University of L'Aquila: 2-years experience. Supportive Care in Cancer. Jun. 2005;13(6):351-5. Not primary care setting. [pmid: 15726432].
682 Potts Y, Gillies ML, Wood SF. Lack of mental well-being in 15-year-olds: an undisclosed iceberg?. Family Practice. Feb. 2001;18(1):95-100. Not integrated care. [pmid: 11145637].
683 Powers CA, Zapka JG, Bognar B, et al. Evaluation of current tobacco curriculum at 12 US medical schools. Journal of Cancer Education. 2004;19(4):212-9. Not mental health condition. [pmid: 15725638].
684 Powers RH, Kniesner TJ, Croghan TW. Psychotherapy and pharmacotherapy in depression. The Journal of Mental Health Policy & Economics. Dec. 2002;5(4):153-61. Not integrated care. [pmid: 14578549].
685 Preville M, Cote G, Boyer R, et al. Detection of depression and anxiety disorders by home care nurses. Aging & Mental Health. Sep. 2004;8(5):400-9. Not integrated care. [pmid: 15511738].
686 Price D. Translating effective depression care into practice: making an impact with. IMPACT General Hospital Psychiatry. Mar–Apr. 2006;28(2):92-3. International. [pmid: 16516057].
687 Priebe S, Gruyters T. The role of the helping alliance in psychiatric community care. Journal of Nervous & Mental Disease. Sep. 1993;181(9):552-7. Not integrated care. [pmid: 8245923].
688 Proudfoot H, Teesson M. Australian National Survey of Mental Health and W. Who seeks treatment for alcohol dependence? Findings from the Australian National Survey of Mental Health and Wellbeing. Social Psychiatry & Psychiatric Epidemiology. Oct. 2002;37(10):451-6. Not integrated care. [pmid: 12242622].
689 Pugliese P, Perrone M, Nisi E, et al. An integrated psychological strategy for advanced colorectal cancer patients. Health & Quality of Life Outcomes. 2006;4:9. Not primary care setting. [pmid: 16460566].
690 Pullen D, Lonie CE, Lyle DM, et al. Medical care of doctors.[see comment]. Medical Journal of Australia. May 1. 1995;162(9):481. Not integrated care. [pmid: 7746206].
691 Qureshi NA, Abdelgadir MH, al-Ghamdy YS, et al. Integration of mental health into primary care in Al-Qassim Region, Saudi Arabia: curriculum development II. Eastern Mediterranean Health Journal. Mar. 1999;5(2):385-8. International. [pmid: 10793817].
692 Qureshi NA, al-Habeeb TA, al-Ghamdy YS, et al. Psychiatric co-morbidity in primary care and hospital referrals, Saudi Arabia. Eastern Mediterranean Health Journal. May. 2001;7(3):492-501. Not primary care setting. [pmid: 12690771].
693 Qureshi NA, Al-Habeeb TA, Al-Ghamdy YS, et al. Psychiatric referrals. In primary care and general hospitals in Qassim Region, Saudi Arabia. Saudi Medical Journal. Jul. 2001;22(7):619-24. Not integrated care. [pmid: 11479646].
694 Qureshi NA, Van Der Molen HT, Schmidt HG, et al. Effectiveness of a training programme for primary care physicians directed at the enhancement of their psychiatric knowledge in Saudi Arabia. Education for Health. Mar. 2006;19(1):52-60. International. [pmid: 16531302].
695 Rabinowitz J, Shayevitz D, Hornik T, et al. Primary care physicians' detection of psychological distress among elderly patients. American Journal of Geriatric Psychiatry. Sep. 2005;13(9):773-80. Not integrated care. [pmid: 16166406].
696 Raine R, Carter S, Sensky T, et al. ‘Referral into a void’: opinions of general practitioners and others on single point of access to mental health care. Journal of the Royal Society of Medicine. Apr. 2005;98(4):153-7. International. [pmid: 15805555].
697 Rapley T, May C, Frances Kaner E. Still a difficult business? Negotiating alcohol-related problems in general practice consultations. Social Science & Medicine. Nov. 2006;63(9):2418-28. International. [pmid: 16814441].
698 Rask KJ, Williams MV, McNagny SE, et al. Ambulatory health care use by patients in a public hospital emergency department. Journal of General Internal Medicine. Sep. 1998;13(9):614-20. Not primary care setting. [pmid: 9754517].
699 Rees CS, Richards JC, Smith LM. Medical utilisation and costs in panic disorder: a comparison with social phobia. Journal of Anxiety Disorders. Sep–Oct. 1998;12(5):421-35. International. [pmid: 9801962].
700 Reeves T, Stace JM. Improving patient access and choice: Assisted Bibliotherapy for mild to moderate stress/anxiety in primary care. Journal of Psychiatric & Mental Health Nursing. Jun. 2005;12(3):341-6. International. [pmid: 15876242].
701 Reich LH, Jaramillo BM, Kaplan LJ, et al. Improving continuity of care: success of a behavioral health program. Journal for Healthcare Quality. Nov–Dec. 2003;25(6):4-8. quiz -9. Not primary care setting. [pmid: 14671850].
702 Reid V, Meadows-Oliver M. Postpartum depression in adolescent mothers: an integrative review of the literature. Journal of Pediatric Health Care. Sep–Oct. 2007;21(5):289-98. Not integrated care. [pmid: 17825726].
703 Renaud J, Chagnon F, Balan B, et al. Psychiatric services utilization in completed suicides of a youth centres population. BMC Psychiatry. 2006;6:36. Not primary care setting. [pmid: 16928279].
704 Repper J, Ford R, Cooke A. How can nurses build trusting relationships with people who have severe and long-term mental health problems?. Journal of Advanced Nursing. Jun. 1994;19(6):1096-104. International. [pmid: 7930090].
705 Reuben DB, Frank JC, Hirsch SH, et al. A randomized clinical trial of outpatient comprehensive geriatric assessment coupled with an intervention to increase adherence to recommendations.[see comment]. Journal of the American Geriatrics Society. Mar. 1999;47(3):269-76. Not mental health condition. [pmid: 10078887].
706 Reuben DB, Maly RC, Hirsch SH, et al. Physician implementation of and patient adherence to recommendations from comprehensive geriatric assessment.[see comment]. American Journal of Medicine. Apr. 1996;100(4):444-51. Not mental health condition. [pmid: 8610732].
707 Richards D. Review: comprehensive organisational and educational interventions appear to be effective for managing depression in primary care. Evidence-Based Nursing. Jan. 2004;7(1):28. Not on target, other publication type. [pmid: 14994701].
708 Richards DA, Lankshear AJ, Fletcher J, et al. Developing a U.K. protocol for collaborative care: a qualitative study. General Hospital Psychiatry. Jul–Aug. 2006;28(4):296-305. International. [pmid: 16814628].
709 Ridgely MS, Willenbring ML. Application of case management to drug abuse treatment: overview of models and research issues. NIDA Research Monograph. 1992;127:12-33. Not mental health condition. [pmid: 1435992].
710 Ridsdale L, Clark LV, Dowson AJ, et al. How do patients referred to neurologists for headache differ from those managed in primary care?. British Journal of General Practice. May. 2007;57(538):388-95. Not mental health condition. [pmid: 17504590].
711 Ridsdale L, Godfrey E, Chalder T, et al. Chronic fatigue in general practice: is counselling as good as cognitive behaviour therapy? A UK randomised trial.[see comment]. British Journal of General Practice. Jan. 2001;51(462):19-24. Not primary care setting. [pmid: 11271868].
712 Ried LD, McConkey JR, Bengtson MA, et al. Weight and blood pressure changes after switching second-generation antipsychotics in a population of veterans with schizophrenia-related disorders. Journal of the American Pharmacists Association: JAPhA. Mar–Apr. 2007;47(2):156-64. Not integrated care. [pmid: 17510002].
713 Rief W, Nanke A. Somatoform disorders in primary care and inpatient settings. Advances in Psychosomatic Medicine. 2004;26:144-58. International. [pmid: 15326868].
714 Riga S, Riga D, Schneider F. Prolongevity medicine: Antagonic-Stress drug in distress, geriatrics, and related diseases. II. Clinical review—2003. Annals of the New York Academy of Sciences. Jun. 2004;1019:401-5. Not integrated care. [pmid: 15247054].
715 Rigatelli M, Casolari L, Massari I, et al. A follow-up study of psychiatric consultations in the general hospital: What happens to patients after discharge?. Psychotherapy Psychosomatics. Sep–Oct. 2001;70(5):276-82. Not primary care setting. [pmid: 11509898].
716 Ring A, Dowrick CF, Humphris GM, et al. The somatising effect of clinical consultation: what patients and doctors say and do not say when patients present medically unexplained physical symptoms. Social Science & Medicine. Oct. 2005;61(7):1505-15. International. [pmid: 15922499].
717 Robertson JR. Treatment of drug misuse in the general practice setting. British Journal of Addiction. Apr. 1989;84(4):377-80. Not mental health condition. [pmid: 2720189].
718 Robins PM, Smith SM, Glutting JJ, et al. A Randomized Controlled Trial of a Cognitive-Behavioral Family Intervention for Pediatric Recurrent Abdominal Pain. Journal of Pediatric Psychology. Jul–Aug. 2005;30(5):397-408. Not primary care setting. [pmid: 15944167].
719 Robinson P. Behavioral health services in primary care: A new perspective for treating depression Clinical Psychology. Science and Practice. Spr. 1998;5(1):77-93. Not on target, other publication type.
720 Robson MH, France R, Bland M. Clinical psychologist in primary care: controlled clinical and economic evaluation. British Medical Journal Clinical Research Ed. Jun 16. 1984;288(6433):1805-8. International. [pmid: 6428555].
721 Rochat S, Wietlisbach V, Burnand B, et al. Success of referral for alcohol dependent patients from a general hospital: predictive value of patient and process characteristics. Substance Abuse. Mar. 2004;25(1):9-15. Not primary care setting. [pmid: 15201107].
722 Rogers G, Curry M, Oddy J, et al. Depressive disorders and unprotected casual anal sex among Australian homosexually active men in primary care. HIV Medicine. Jul. 2003;4(3):271-5. Not integrated care. [pmid: 12859327].
723 Rollman BL. Reflections on the 10th Anniversary of the AHCPR's Guideline for the Treatment of Depression in Primary Care. Journal of General Internal Medicine. Jun. 2003;18(6):492-3. Not on target, other publication type. [pmid: 12823658].
724 Rollnick S. “Screening and brief intervention for excessive alcohol use: Qualitative interview and study of the experienced practitioners”: Comment. BMJ: British Medical Journal. Feb. 2003;326(7384):336. International.
725 Romans-Clarkson SE, Walton VA, Dons DJ, et al. Which women seek help for their psychiatric problems?[see comment]. New Zealand Medical Journal. Sep 26. 1990;103(898):445-8. Not integrated care. [pmid: 2216111].
726 Romelsjo A, Andersson L, Barrner H, et al. A randomized study of secondary prevention of early stage problem drinkers in primary health care.[erratum appears in Br J Addict 1990 Mar;85(3):431]. British Journal of Addiction. Nov. 1989;84(11):1319-27. International. [pmid: 2597808].
727 Ronalds C, Kapur N, Stone K, et al. Determinants of consultation rate in patients with anxiety and depressive disorders in primary care. Family Practice. Feb. 2002;19(1):23-8. Not integrated care. [pmid: 11818346].
728 Rosenfield S, Caton C, Nachumi G, et al. Closing the gaps: the effectiveness of linking programs connecting chronic mental patients from the hospital to the community. Journal of Applied Behavioral Science. 1986;22(4):411-23. Not primary care setting. [pmid: 10280321].
729 Rost K, Humphrey J, Kelleher K. Physician management preferences and barriers to care for rural patients with depression. Archives of Family Medicine. May. 1994;3(5):409-14. Not on target, other publication type. [pmid: 8032501].
730 Rost K, Kashner TM, Smith RG Jr. Effectiveness of psychiatric intervention with somatization disorder patients: improved outcomes at reduced costs.[see comment]. General Hospital Psychiatry. Nov. 1994;16(6):381-7. Not on target, other publication type. [pmid: 7843574].
731 Rothbard AB, Min SY, Kuno E, et al. Long-term effectiveness of the ACCESS program in linking community mental health services to homeless persons with serious mental illness. Journal of Behavioral Health Services Research. Oct–Dec. 2004;31(4):441-9. Not integrated care. [pmid: 15602144].
732 Rumpf HJ, Bohlmann J, Hill A, et al. Physicians' low detection rates of alcohol dependence or abuse: a matter of methodological shortcomings?. General Hospital Psychiatry. May–Jun. 2001;23(3):133-7. Not integrated care. [pmid: 11427245].
733 Runeson B. Parasuicides without follow-up. Nordic Journal of Psychiatry. 2001;55(5):319-23. Not primary care setting. [pmid: 11839122].
734 Ruof J, Mittendorf T, Pirk O, et al. Diffusion of innovations: treatment of Alzheimer's disease in Germany. Health Policy. Apr. 2002;60(1):59-66. Not mental health condition. [pmid: 11879945].
735 Rushton J, Bruckman D, Kelleher K. Primary care referral of children with psychosocial problems Archives of Pediatrics & Adolescent. Medicine. Jun. 2002;156(6):592-8. Not integrated care.
736 Rushton JL, Clark SJ, Freed GL. Pediatrician and family physician prescription of selective serotonin reuptake inhibitors. Pediatrics. Jun. 2000;105(6):E82. Not integrated care. [pmid: 10835095].
737 Rutchik SD, Baudiere M, Wade M, et al. Practice patterns in the diagnosis and treatment of erectile dysfunction among family practice physicians. Urology. Jan. 2001;57(1):146-50. Not mental health condition. [pmid: 11164161].
738 Ryall C, Coggon D, Peveler R, et al. A prospective cohort study of arm pain in primary care and physiotherapy—prognostic determinants. Rheumatology. Mar. 2007;46(3):508-15. Not mental health condition. [pmid: 16973688].
739 Ryan M, Gevirtz R. Biofeedback-based psychophysiological treatment in a primary care setting: an initial feasibility study. Applied Psychophysiology & Biofeedback. Jun. 2004;29(2):79-93. not included study design. [pmid: 15208972].
740 Ryan M, Nitsun M, Gilbert L, et al. A prospective study of the effectiveness of group and individual psychotherapy for women CSA survivors. Psychology & Psychotherapy: Theory Research & Practice. Dec. 2005;78(Pt 4):465-79. International.
741 Ryan T, Hatfield B, Sharma I. Outcomes of referrals over a six-month period to a mental health gateway team. Journal of Psychiatric & Mental Health Nursing. Sep. 2007;14(6):527-34. International. [pmid: 17718724].
742 Saarikoski M. Mentor relationship as a tool of professional development of student nurses in clinical practice. International Journal of Psychiatric Nursing Research. Sep. 2003;9(1):1014-24. Not integrated care. [pmid: 14533232].
743 Saitz R. Alcohol dependence: Chronic care for a chronic disease. Jornal Brasileiro de Psiquiatria. Oct–Dec. 2005;54(4):268-9. Not on target, other publication type.
744 Saltz Corley C, Davis P, Jackson L, et al. Spirit of aging rising: cross-cutting thematic modules to enrich foundation graduate social work courses. Journal of Gerontological Social Work. 2007;48(34):299-309. Medical education. [pmid: 17210534].
745 Samet JH, Larson MJ, Horton NJ, et al. Linking alcohol- and drug-dependent adults to primary medical care: a randomized controlled trial of a multi-disciplinary health intervention in a detoxification unit. Addiction. Apr. 2003;98(4):509-16. Not primary care setting. [pmid: 12653820].
746 Sanchez-Craig M. Brief didactic treatment for alcohol and drug-related problems: an approach based on client choice. British Journal of Addiction. Feb. 1990;85(2):169-77. International. [pmid: 2317584].
747 Sanders MR, Tully LA, Turner KM, et al. Training GPs in parent consultation skills. An evaluation of training for the Triple P-Positive Parenting Program. Australian Family Physician. Sep. 2003;32(9):763-8. Not mental health condition. [pmid: 14524224].
748 Sanders MR, Turner KM, Markie-Dadds C. The development and dissemination of the Triple P-Positive Parenting Program: a multilevel, evidence-based system of parenting and family support. Prevention Science. Sep. 2002;3(3):173-89. Not mental health condition. [pmid: 12387553].
749 Santiago JM, McCall-Perez F, Bachrach LL. Integrated services for chronic mental patients: theoretical perspective and experimental results. General Hospital Psychiatry. Oct. 1985;7(4):309-15. Not on target, other publication type. [pmid: 4065549].
750 Saraceno B, Briceno RA, Asioli F, et al. Cooperation in mental health: an Italian project in Nicaragua. Social Science & Medicine. 1990;31(9):1067-71. Not integrated care. [pmid: 2255966].
751 Sax L, Kautz KJ. Who first suggests the diagnosis of attention-deficit/hyperactivity disorder?. Annals of Family Medicine. Sep–Oct. 2003;1(3):171-4. Not integrated care. [pmid: 15043379].
752 Scanlan M, Smart D, Gregory S, et al. Evaluation of the effect of practice nurses on the management of depression. Primary Care Mental Health. 2006;4(2):107-12. International.
753 Schackman BR, Teixeira PA, Beeder AB. Offers of hepatitis C care do not lead to treatment. Journal of Urban Health. May. 2007;84(3):455-8. Not mental health condition. [pmid: 17394085].
754 Schlenger WE, Kroutil LA, Roland EJ. Case management as a mechanism for linking drug abuse treatment and primary care: preliminary evidence from the ADAMHA/HRSA linkage demonstration. NIDA Research Monograph. 1992;127:316-30. Not mental health condition. [pmid: 1331803].
755 Scholle SH, Haskett RF, Hanusa BH, et al. Addressing depression in obstetrics/gynecology practice. General Hospital Psychiatry. Mar–Apr. 2003;25(2):83-90. Not included study design. [pmid: 12676420].
756 Schriger DL, Gibbons PS, Langone CA, et al. Enabling the diagnosis of occult psychiatric illness in the emergency department: a randomized, controlled trial of the computerized, self-administered PRIME-MD diagnostic system. Annals of Emergency Medicine. Feb. 2001;37(2):132-40. Not primary care setting. [pmid: 11174229].
757 Schulberg HC, Burns BJ. Mental disorders in primary care: epidemiologic, diagnostic, and treatment research directions. General Hospital Psychiatry. Mar. 1988;10(2):79-87. Not on target, other publication type. [pmid: 3282988].
758 Schulberg HC, Katon W, Simon GE, et al. Treating major depression in primary care practice: an update of the Agency for Health Care Policy and Research Practice Guidelines. Archives of General Psychiatry. Dec. 1998;55(12):1121-7. Not on target, other publication type. [pmid: 9862556].
759 Scott DM. Transition of patients with sickle cell disease from pediatric care to adult care: Implications for positive disease self-management in transition Scott, Dena Marie: The Wright Inst, US; 2007. Not mental health condition
760 Scott J, Thorne A, Horn P. Quality improvement report: Effect of a multifaceted approach to detecting and managing depression in primary care. BMJ. Oct 26. 2002;325(7370):951-4. International. [pmid: 12399349].
761 Seale JP, Sparks T, Robbins L, et al. Successful physician interventions with hospitalized alcoholic patients. Journal of the American Board of Family Practice. Jul–Aug. 1992;5(4):433-6. Not primary care setting. [pmid: 1323201].
762 Seivewright H, Tyrer P, Casey P, et al. A three-year follow-up of psychiatric morbidity in urban and rural primary care. Psychological Medicine. May. 1991;21(2):495-503. Not integrated care. [pmid: 1876654].
763 Selby JV, Grumbach K, Quesenberry CP J, et al. Differences in resource use and costs of primary care in a large HMO according to physician specialty.[see comment]. Health Services Research. Jun. 1999;34(2):503-18. Not integrated care. [pmid: 10357287].
764 Seligman R, Rauh JL. Psychiatric consultation in a medical setting for adolescents. Description of one modus operandi. Clinical Pediatrics. Feb. 1974;13(2):117-20. Not primary care setting. [pmid: 4810695].
765 Selman L, Harding R, Beynon T, et al. Improving end-of-life care for patients with chronic heart failure: “Let's hope it'll get better, when I know in my heart of hearts it won't”. Heart. Aug. 2007;93(8):963-7. Not mental health condition. [pmid: 17309905].
766 Sensky T, MacLeod AK, Rigby MF. Causal attributions about common somatic sensations among frequent general practice attenders. Psychological Medicine. May. 1996;26(3):641-6. Not integrated care. [pmid: 8733222].
767 Shah R, McNiece R, Majeed A. General practice consultation rates for psychiatric disorders in patients aged 65 and over: prospective cohort study. International Journal of Geriatric Psychiatry. Jan. 2001;16(1):57-63. Not integrated care. [pmid: 11180486].
768 Shapley M, Jordan K, Croft PR. An investigation in primary care of the relationship between consultation behaviour, increased vaginal bleeding and mental disorder. Journal of Obstetrics & Gynaecology. Sep. 2004;24(6):684-6. Not integrated care. [pmid: 16147612].
769 Sharp DM, Power KG, Swanson V. Reducing therapist contact in cognitive behaviour therapy for panic disorder and agoraphobia in primary care: global measures of outcome in a randomised controlled trial. British Journal of General Practice. Dec. 2000;50(461):963-8. International. [pmid: 11224967].
770 Shaughnessy A. In patients who do not respond to antidepressants or who are at risk for recurrence, is collaborative care effective?. Evidence-Based Practice. Feb. 2003;6(2):9-2. International.
771 Shaw CM, Creed F, Babbs C, et al. Referral of Asian patients to a GI clinic. Journal of Psychosomatic Research. Nov. 1996;41(5):473-9. Not primary care setting. [pmid: 9032711].
772 Shaw I, Smith KM, Middleton H, et al. A letter of consequence: referral letters from general practitioners to secondary mental health services. Qualitative Health Research. Jan. 2005;15(1):116-28. International. [pmid: 15574719].
773 Shaw K, Wagner I, Eastwood H, et al. A qualitative study of Australian GPs' attitudes and practices in the diagnosis and management of attention-deficit/hyperactivity disorder (ADHD). Family Practice. Apr. 2003;20(2):129-34. International. [pmid: 12651785].
774 Shear K, Belnap BH, Mazumdar S, et al. Generalized anxiety disorder severity scale (GADSS): a preliminary validation study. Depression & Anxiety. 2006;23(2):77-82. Not integrated care. [pmid: 16411185].
775 Shega JW, Levin A, Hougham GW, et al. Palliative Excellence in Alzheimer Care Efforts (PEACE): a program description. Journal of Palliative Medicine. Apr. 2003;6(2):315-20. Not primary care setting. [pmid: 12854952].
776 Shemesh E, Yehuda R, Rockmore L, et al. Assessment of depression in medically ill children presenting to pediatric specialty clinics. Journal of the American Academy of Child & Adolescent Psychiatry. Dec. 2005;44(12):1249-57. Not integrated care. [pmid: 16292116].
777 Shern DL, Wilson NZ, Coen AS, et al. Client outcomes II: Longitudinal client data from the Colorado treatment outcome study. Milbank Quarterly. 1994;72(1):123-48. Not on target, other publication type. [pmid: 8164605].
778 Shevell MI, Majnemer A, Rosenbaum P, et al. Profile of referrals for early childhood developmental delay to ambulatory subspecialty clinics. Journal of Child Neurology. Sep. 2001;16(9):645-50. Not integrated care. [pmid: 11575603].
779 Shilling KH, Bass RL. Use of adult psychiatric services by primary care physicians in midwestern cities. Nebraska Medical Journal. Mar. 1990;75(3):37-42. Not integrated care. [pmid: 2314513].
780 Sices L, Feudtner C, McLaughlin J, et al. How do primary care physicians manage children with possible developmental delays? A national survey with an experimental design. Pediatrics. Feb. 2004;113(2):274-82. Not integrated care. [pmid: 14754938].
781 Sigel P, Leiper R. GP views of their management and referral of psychological problems: a qualitative study. Psychology & Psychotherapy: Theory, Research & Practice. Sep. 2004;77(Pt 3):279-95. Not integrated care.
782 Silverstein M, Sand N, Glascoe FP, et al. Pediatrician practices regarding referral to early intervention services: is an established diagnosis important?. Ambulatory Pediatrics. Mar–Apr. 2006;6(2):105-9. Not integrated care. [pmid: 16530148].
783 Simoens S, Gordon C, Scott A. Evaluating the effect of new hospital specialties on GP prescription costs. Health Policy. Jul. 2000;52(3):171-8. Not primary care setting. [pmid: 10862992].
784 Simon C, Eder M, Raiz P, et al. Informed consent for pediatric leukemia research: clinician perspectives. Cancer. Aug 1. 2001;92(3):691-700. Not mental health condition. [pmid: 11505417].
785 Simon GE. Can depression be managed appropriately in primary care?. Journal of Clinical Psychiatry. 1998;59(Suppl 2):3-8. Not on target, other publication type. [pmid: 9559753].
786 Simons L, Lathlean J, Kendrick T. Community mental health nurses' views of their role in the treatment of people with common mental disorders. Primary Care Mental Health. 2006;4(2):121-9. International.
787 Simpson RJ, Kazmierczak T, Power KG, et al. Controlled comparison of the characteristics of patients with panic disorder. British Journal of General Practice. Aug. 1994;44(385):352-6. Not integrated care. [pmid: 8068393].
788 Sims AC, Salmons PH. Severity of symptoms of psychiatric outpatients: use of the General Health Questionnaire in hospital ang general practice patients. Psychological Medicine. Feb. 1975;5(1):62-6. Not integrated care. [pmid: 1118532].
789 Sixma HJ, de Bakker DH. Hospital or general practice? Results of two experiments limiting the number of self referrals of patients with injuries to hospitals in The Netherlands. Journal of Accident & Emergency Medicine. Jul. 1996;13(4):264-8. Not primary care setting. [pmid: 8832346].
790 Skelton JR, Hobbs FD. Concordancing: use of language-based research in medical communication. Lancet. Jan 9. 1999;353(9147):108-11. Not integrated care. [pmid: 10023896].
791 Skevington SM, Lotfy M, O'Connell KA, et al. The World Health Organization's WHOQOL-BREF quality of life assessment: psychometric properties and results of the international field trial. Quality of Life Research. Mar. 2004;13(2):299-310. Not integrated care. [pmid: 15085902].
792 Skirton H. Parental experience of a pediatric genetic referral. MCN: The American Journal of Maternal/Child Nursing. May–Jun. 2006;31(3):178-84. Not integrated care.
793 Sladden MJ, Hughes AM, Hirst GH, et al. A community study of lower urinary tract symptoms in older men in Sydney, Australia. Australian & New Zealand Journal of Surgery. May. 2000;70(5):322-8. Not mental health condition. [pmid: 10830592].
794 Sladden MJ, Thomson AN. An evaluation of a surveillance system for patients discharged from the acute psychiatry unit in southern Tasmania. Australian & New Zealand Journal of Psychiatry. Jun. 1999;33(3):385-91. Not primary care setting. [pmid: 10442795].
795 Slimmer L. A collaborative care management programme in a primary care setting was effective for older adults with late life depression. Evidence-Based Nursing. Jul. 2003;6(3):91. International. [pmid: 12882204].
796 Smeeton N, Wilkinson G, Skuse D, et al. A longitudinal study of general practitioner consultations for psychiatric disorders in adolescence. Psychological Medicine. Aug. 1992;22(3):709-15. Not integrated care. [pmid: 1410094].
797 Smith GR J, Rost K, Kashner TM. A trial of the effect of a standardized psychiatric consultation on health outcomes and costs in somatizing patients. Archives of General Psychiatry. Mar. 1995;52(3):238-43. Not integrated care. [pmid: 7872852].
798 Smith MT, Neubauer DN. Cognitive behavior therapy for chronic insomnia. Clinical Cornerstone. 2003;5(3):28-40. Not mental health condition. [pmid: 14626539].
799 Smith RC, Lein C, Collins C, et al. Treating patients with medically unexplained symptoms in primary care. Journal of General Internal Medicine. Jun. 2003;18(6):478-89. Not integrated care. [pmid: 12823656].
800 Sobel AB, Roberts MC, Rayfield AD, et al. Evaluating outpatient pediatric psychology services in a primary care setting. Journal of Pediatric Psychology. Oct–Nov. 2001;26(7):395-405. Not included study design. [pmid: 11553694].
801 Sokhela NE, Uys LR. The integration of the rehabilitation of psychiatric patients into the primary health care system. Curationis. Dec. 1998;21(4):8-13. International. [pmid: 11040594].
802 Sokol RJ, Rosen MG, Stojkov J, et al. Clinical application of high-risk scoring on an obstetric service. American Journal of Obstetrics & Gynecology. Jul 15. 1977;128(6):652-61. Not integrated care. [pmid: 879223].
803 Solberg LI, Fischer LR, Wei F, et al. A CQI intervention to change the care of depression: a controlled study.[see comment]. Effective Clinical Practice. Nov–Dec. 2001;4(6):239-49. Not included study design. [pmid: 11769296].
804 Solomon P, Draine J. Issues in serving the forensic client. Social Work. Jan. 1995;40(1):25-33. Not primary care setting. [pmid: 7863370].
805 Somerset M, Faulkner A, Shaw A, et al. Obstacles on the path to a primary-care led National Health Service: complexities of outpatient care. Social Science & Medicine. Jan. 1999;48(2):213-25. Not integrated care. [pmid: 10048779].
806 Soon JA, Levine M. Screening for depression in patients in long-term care facilities: a randomized controlled trial of physician response. Journal of the American Geriatrics Society. Jun. 2002;50(6):1092-9. Not primary care setting. [pmid: 12110071].
807 Sorgaard KW, Sandanger I, Sorensen T, et al. Mental disorders and referrals to mental health specialists by general practitioners. Social Psychiatry & Psychiatric Epidemiology. Mar. 1999;34(3):128-35. Not integrated care. [pmid: 10327837].
808 Soto TA, Bell J, Pillen MB, et al. Literature on integrated HIV care: a review. AIDS Care. 2004;16(Suppl 1):S43-55. Not mental health condition. [pmid: 15736821].
809 Soumenkoff G, Marneffe C, Gerard M, et al. A coordinated attempt for prevention of child abuse at the antenatal care level. Child Abuse & Neglect. 1982;6(1):87-94. Not integrated care. [pmid: 6892289].
810 Southern L, Leahey M, Harper-Jaques S, et al. Integrating mental health into urgent care in a community health centre. Canadian Nurse. Jan. 2007;103(1):29-34. International. [pmid: 17269582].
811 Spangler JG, Enarson C, Eldridge C. An integrated approach to a tobacco-dependence curriculum. Academic Medicine. May. 2001;76(5):521-2. Not mental health condition. [pmid: 11346561].
812 Sperry L, Brill PL, Howard KI, et al. Treatment outcomes in psychotherapy and psychiatric interventions Philadelphia, PA: Brunner/Mazel; 1996. Not on target, other publication type
813 Spikes J, Gadlin W. Ombudsman rounds revisited—a controlled study of attitudinal change in response to liaison psychiatry teaching. General Hospital Psychiatry. Jul. 1986;8(4):273-8. Medical education. [pmid: 3744036].
814 Spurrell M, Hatfield B, Perry A. Characteristics of patients presenting for emergency psychiatric assessment at an English hospital. Psychiatric Services. Feb. 2003;54(2):240-5. Not primary care setting. [pmid: 12556607].
815 Squires T, Gorman D. Suicide by young men in Lothian 1993 and 1994. Health Bulletin. Nov. 1996;54(6):458-66. Not integrated care. [pmid: 8990611].
816 Standing P. A 10-step approach to successful hypertension management in practice. Guidelines in Practice. Dec. 2005;8(12):24-7. 9. Not mental health condition.
817 Steadman HJ, Cocozza JJ, Dennis DL, et al. Successful program maintenance when federal demonstration dollars stop: the ACCESS program for homeless mentally ill persons. Administration & Policy in Mental Health. Jul. 2002;29(6):481-93. Not primary care setting. [pmid: 12469702].
818 Steadman HJ, Morris SM, Dennis DL. The diversion of mentally ill persons from jails to community-based services: a profile of programs.[see comment]. American Journal of Public Health. Dec. 1995;85(12):1630-5. Not primary care setting. [pmid: 7503336].
819 Stiefel F, Stagno D. Management of insomnia in patients with chronic pain conditions. CNS Drugs. 2004;18(5):285-96. Not mental health condition. [pmid: 15089114].
820 Stiles WB, Barkham M, Twigg E, et al. Effectiveness of cognitive-behavioural, person-centred and psychodynamic therapies as practised in UK National Health Service settings. Psychological Medicine. Apr. 2006;36(4):555-66. International. [pmid: 16476185].
821 Stoessel PW, Bystritsky A, Pasnau RO. Screening for anxiety disorders in the primary care setting. Family Practice. Dec. 1995;12(4):448-51. Not integrated care. [pmid: 8826064].
822 Stojanovski SD, Rasu RS, Balkrishnan R, et al. Trends in medication prescribing for pediatric sleep difficulties in US outpatient settings. Sleep. Aug 1. 2007;30(8):1013-7. Not integrated care. [pmid: 17702271].
823 Strain JJ, George LK, Pincus HA, et al. Models of mental health training for primary care physicians: a validation study. Psychosomatic Medicine. Jan–Feb. 1987;49(1):88-98. Medical education. [pmid: 3823354].
824 Straus SM, Bleumink GS, Dieleman JP, et al. Antipsychotics and the risk of sudden cardiac death.[erratum appears in Arch Intern Med. 2004 Sep 27;164(17):1839]. Archives of Internal Medicine. Jun 28. 2004;164(12):1293-7. Not integrated care. [pmid: 15226162].
825 Sugarman LI. Hypnosis in a primary care practice: developing skills for the “new morbidities”. Journal of Developmental & Behavioral Pediatrics. Oct. 1996;17(5):300-5. Not mental health condition. [pmid: 8897216].
826 Sullivan LE, Bruce RD, Haltiwanger D, et al. Initial strategies for integrating buprenorphine into HIV care settings in the United States. Clinical Infectious Diseases. Dec 15. 2006;43(Suppl 4):S191-6. Not mental health condition. [pmid: 17109306].
827 Suppes T, McElroy SL, Hirschfeld R. Awareness of metabolic concerns and perceived impact of pharmacotherapy in patients with bipolar disorder: a survey of 500 US psychiatrists. Psychopharmacology Bulletin. 2007;40(2):22-37. quiz 8–40. Not integrated care. [pmid: 17514184].
828 Sutor B, Agerter DC. Collaborative psychiatric care in a rural family medicine setting reduces health care utilization in depressed patient. Minnesota Medicine. Jan. 2007;90(1):39-41. not included study design. [pmid: 17305104].
829 Svab I, Zaletel-Kragelj L. Frequent attenders in general practice: a study from Slovenia Scandinavian. Journal of Primary Health Care. Mar. 1993;11(1):38-43. Not integrated care.
830 Sved Williams A, Dodding J, Wilson I, et al. Consultation-liaison to general practitioners coming of age: the South Australian psychiatrists' experience. Australasian Psychiatry. Jun. 2006;14(2):206-11. International. [pmid: 16734652].
831 Svenson LW, Forster DI, Woodhead SE, et al. Individuals with a chemical-dependent family member. Does their health care use increase?. Canadian Family Physician. Sep. 1995;41:1488-93. Not integrated care. [pmid: 8520237].
832 Swanson JG. Family physicians' approach to psychotherapy and counseling. Perceptions and practices.[see comment]. Canadian Family Physician. Jan. 1994;40:53-8. International. [pmid: 8080505].
833 Sweeney KG, Gray DP. Patients who do not receive continuity of care from their general practitioner—are they a vulnerable group?[see comment]. British Journal of General Practice. Mar. 1995;45(392):133-5. Not integrated care. [pmid: 7772390].
834 Sweeney LP, Samet JH, Larson MJ, et al. Establishment of a multidisciplinary Health Evaluation and Linkage to Primary care (HELP) clinic in a detoxification unit. Journal of Addictive Diseases. 2004;23(2):33-45. Not primary care setting. [pmid: 15132341].
835 Sweeney P, Kisely S. Barriers to managing mental health in Western Australia. Australian Journal of Rural Health. Aug. 2003;11(4):205-10. International. [pmid: 14641234].
836 Swigar ME, Sanguineti VR, Piscatelli RL. A retrospective study on the perceived need for and actual use of psychiatric consultations in older medical patients. International Journal of Psychiatry in Medicine. 1992;22(3):239-49. Not integrated care. [pmid: 1487387].
837 Symons L, Tylee A, Mann A, et al. Improving access to depression care: descriptive report of a multidisciplinary primary care pilot service. British Journal of General Practice. Sep. 2004;54(506):679-83. International. [pmid: 15353054].
838 Szanto K, Kalmar S, Hendin H, et al. A suicide prevention program in a region with a very high suicide rate. Archives of General Psychiatry. Aug. 2007;64(8):914-20. International. [pmid: 17679636].
839 Tait L, Lester H, Birchwood M, et al. Design of the BiRmingham Early Detection In untREated psyChosis Trial (REDIRECT): cluster randomised controlled trial of general practitioner education in detection of first episode psychosis [ISRCTN87898421]. BMC Health Services Research. Mar 8. 2005;5(1):19. Not integrated care. [pmid: 15755321].
840 Tait RJ, Hulse GK, Robertson SI, et al. Emergency department-based intervention with adolescent substance users: 12-month outcomes. Drug & Alcohol Dependence. Sep 1. 2005;79(3):359-63. Not primary care setting. [pmid: 16102378].
841 Talbott JA, Jefferies M, Arana JD. CMHC's: relationships with academia and the state. Community Mental Health Journal. 1987;23(4):271-81. Not integrated care. [pmid: 3440379].
842 Tardieu S, Bottero A, Blin P, et al. Roles and practices of general practitioners and psychiatrists in management of depression in the community. BMC Family Practice. 2006;7:5. Not integrated care. [pmid: 16445855].
843 Tarride JE, Gordon A, Vera-Llonch M, et al. Cost-Effectiveness of Pregabalin for the Management of Neuropathic Pain Associated with Diabetic Peripheral Neuropathy and Postherpetic Nerualgia: A Canadian Perspective Clinical Therapeutics: The International Peer-Reviewed. Journal of Drug Therapy. Nov. 2006;28(11):1922-34. Not integrated care.
844 Tata P, Eagle A, Green J. Does providing more accessible primary care psychology services lower the clinical threshold for referrals?. British Journal of General Practice. Aug. 1996;46(409):469-72. International. [pmid: 8949326].
845 Teague GB, Drake RE, Ackerson TH. Evaluating use of continuous treatment teams for persons with mental illness and substance abuse. Psychiatric Services. Jul. 1995;46(7):689-95. Not primary care setting. [pmid: 7552560].
846 Ten Have M, Vollebergh W, Bijl R, et al. Combined effect of mental disorder and low social support on care service use for mental health problems in the Dutch general population. Psychological Medicine. Feb. 2002;32(2):311-23. Not integrated care. [pmid: 11866325].
847 Theis GA, Kozlowski D, Behrens J. In-home behavioral health case management: an integrated model for high-risk populations. Case Manager. Nov–Dec. 2006;17(6):60-5. Not primary care setting. [pmid: 17167870].
848 Thijs GA. GP's consult and health behaviour change project. Developing a programme to train GPs in communication skills to achieve lifestyle improvements. Patient Education & Counseling. Aug. 2007;67(3):267-71. International. [pmid: 17590302].
849 Thomas C, Cromwell J, Miller H. Community mental health teams' perspectives on providing care for deaf people with severe mental illness. Journal of Mental Health. Jun. 2006;15(3):301-13. International.
850 Thomas DP, Heller RF, Hunt JM. Clinical consultations in an aboriginal community-controlled health service: a comparison with general practice. Australian & New Zealand Journal of Public Health. Feb. 1998;22(1):86-91. International. [pmid: 9599858].
851 Thomas E, Boardman HF, Ogden H, et al. Advice and care for headaches: who seeks it, who gives it?. Cephalalgia. Sep. 2004;24(9):740-52. Not mental health condition. [pmid: 15315530].
852 Thomas K, Secker J, Grove B. Qualitative evaluation of a job retention pilot for people with mental health problems. British Journal of General Practice. Jul. 2005;55(516):546-7. International. [pmid: 16004742].
853 Thomas KB. Temporarily dependent patient in general practice. British Medical Journal. Mar 30. 1974;1(5908):625-6. International. [pmid: 4821014].
854 Thomas-MacLean R, Stoppard JM. Physicians' constructions of depression: inside/outside the boundaries of medicalization Health: an Interdisciplinary. Journal for the Social Study of Health, Illness & Medicine. Jul. 2004;8(3):275-93. International.
855 Thompson C, Kinmonth AL, Stevens L, et al. Effects of a clinical-practice guideline and practice-based education on detection and outcome of depression in primary care: Hampshire Depression Project randomised controlled trial. Lancet. Jan 15. 2000;355(9199):185-91. International. [pmid: 10675118].
856 Thompson C, Thompson CM. Treatment resistant or irresolutely treated?. International Clinical Psychopharmacology. Jul. 1991;6(Suppl 1):31-8. discussion 8–9. International. [pmid: 1757717].
857 Thompson EE, Neighbors HW, Munday C, et al. Length of stay, referral to aftercare, and rehospitalization among psychiatric inpatients.[see comment]. Psychiatric Services. Sep. 2003;54(9):1271-6. Not primary care setting. [pmid: 12954945].
858 Tiller JW, Biddle N. Obtaining outpatient referrals for clinical research. Australian & New Zealand Journal of Psychiatry. Mar. 1991;25(1):132-3. Not integrated care. [pmid: 1675563].
859 Tod AM, Read C, Lacey A, et al. Barriers to uptake of services for coronary heart disease: qualitative study. BMJ. Jul 28. 2001;323(7306):214. Not mental health condition. [pmid: 11473916].
860 Tommasello AC, Gillis LM, Lawler JT, et al. Characteristics of homeless HIV-positive outreach responders in urban US and their success in primary care treatment. AIDS Care. Nov. 2006;18(8):911-7. Not mental health condition. [pmid: 17012080].
861 Tommet PA, York JL, Tomlinson PS, et al. Graduate nursing education: developmental disabilities and special health care needs Issues in Comprehensive. Pediatric Nursing. Oct–Dec. 1993;16(4):239-58. Not integrated care.
862 Townsend JA. Psychiatric inpatient unit and outpatient clinic liaison service. Journal of Psychiatric Nursing & Mental Health Services. Mar. 1976;14(3):7-9. Not primary care setting. [pmid: 176355].
863 Tracy SW, Trafton JA, Weingardt KR, et al. How are substance use disorders addressed in VA psychiatric and primary care settings?. Results of a national survey Psychiatric Services. Feb. 2007;58(2):266-9. Not integrated care. [pmid: 17287386].
864 Tresolini CP, Shugars DA. An integrated health care model in medical education: interviews with faculty and administrators. Academic Medicine. Mar. 1994;69(3):231-6. e. [pmid: 8135981].
865 Trifiro G, Verhamme KM, Ziere G, et al. All-cause mortality associated with atypical and typical antipsychotics in demented outpatients. Pharmacoepidemiology & Drug Safety. May. 2007;16(5):538-44. Not integrated care. [pmid: 17036366].
866 Trotter JM, Scott R, Macbeth FR, et al. Problems of the oncology outpatient: role of the liaison health visitor. British Medical Journal Clinical Research Ed. Jan 10. 1981;282(6258):122-4. Not primary care setting. [pmid: 6779901].
867 Tuchman E, Gregory C, Simson JM, et al. Office-based opioid treatment (OBOT): practitioner's knowledge, attitudes, and expectations in New Mexico... second in a series. Addictive Disorders & Their Treatment. Mar. 2005;4(1):11-9. Not mental health condition.
868 Tummey R. A collaborative approach to urgent mental health referrals. Nursing Standard. Sep 12–18. 2001;15(52):39-42. International. [pmid: 12205857].
869 Turk DC, Gatchel RJ. Psychological approaches to pain management: A practitioner's handbook (2nd ed.) New York, NY: Guilford Press; 2002. Not on target, other publication type
870 Turnbull S, Ward A, Treasure J, et al. The demand for eating disorder care. An epidemiological study using the general practice research database. British Journal of Psychiatry. Dec. 1996;169(6):705-12. Not integrated care. [pmid: 8968627].
871 Tyrer P, Casey PR, Seivewright H, et al. A survey of the treatment of anxiety disorders in general practice. Postgraduate Medical Journal. 1988;64(Suppl 2):27-31. Not integrated care. [pmid: 3217301].
872 Tzeng DS, Lian LC, Chang CU, et al. Healthcare in schizophrenia: effectiveness and progress of a redesigned care network. BMC Health Services Research. 2007;7:129. International. [pmid: 17705853].
873 Unutzer J, Simon G, Belin TR, et al. Care for depression in HMO patients aged 65 and older.[see comment]. Journal of the American Geriatrics Society. Aug. 2000;48(8):871-8. Not integrated care. [pmid: 10968289].
874 Upchurch SL. A collaborative care intervention improved depression outcomes, but not glycaemic control, in diabetes and comorbid depression. Evidence-Based Nursing. Jul. 2005;8(3):81. International. [pmid: 16021710].
875 Vagholkar S, Hare L, Hasan I, et al. Better access to psychology services in primary mental health care: an evaluation. Australian Health Review. May. 2006;30(2):195-202. International. [pmid: 16646768].
876 Valuck RJ, Libby AM, Orton HD, et al. Spillover effects on treatment of adult depression in primary care after FDA advisory on risk of pediatric suicidality with SSRIs. American Journal of Psychiatry. Aug. 2007;164(8):1198-205. Not integrated care. [pmid: 17671282].
877 van den Brink W, Leenstra A, Ormel J, et al. Mental health intervention programs in primary care: their scientific basis. Journal of Affective Disorders. Apr. 1991;21(4):273-84. International. [pmid: 1676711].
878 van den Heuvel-Janssen HA, Borghouts JA, Muris JW, et al. Chronic non-specific abdominal complaints in general practice: a prospective study on management, patient health status and course of complaints. BMC Family Practice. 2006;7:12. Not mental health condition. [pmid: 16512926].
879 van der Feltz-Cornelis CM, Meeuwissen JA, de Jong FJ, et al. Randomised controlled trial of a psychiatric consultation model for treatment of common mental disorder in the occupational health setting. BMC Health Services Research. 2007;7:29. Not primary care setting. [pmid: 17326830].
880 van der Feltz-Cornelis CM, van Oppen P, Ader HJ, et al. Randomised controlled trial of a collaborative care model with psychiatric consultation for persistent medically unexplained symptoms in general practice. Psychotherapy & Psychosomatics. 2006;75(5):282-9. International. [pmid: 16899964].
881 van Dulmen AM, Fennis JF, Mokkink HG, et al. The relationship between complaint-related cognitions in referred patients with irritable bowel syndrome and subsequent health care seeking behaviour in primary care. Family Practice. Feb. 1996;13(1):12-7. Not mental health condition. [pmid: 8671098].
882 van Hout H, Vernooij-Dassen M, Poels P, et al. Applicability of diagnostic recommendations on dementia in family practice. International Journal for Quality in Health Care. Apr. 2001;13(2):127-33. Not mental health condition. [pmid: 11430662].
883 van Marwijk H, Gercama A, Ader H, et al. Mean clinical challenge rate and level of recognition of depression remain unchanged after two years of vocational training. Family Practice. Dec. 2001;18(6):590-1. Medical education. [pmid: 11739342].
884 Van Os TW, Van den Brink RH, Van der Meer K, et al. The care provided by general practitioners for persistent depression. European Psychiatry: the Journal of the Association of European Psychiatrists. Mar. 2006;21(2):87-92. Not integrated care. [pmid: 16137864].
885 van Weert JC, Janssen BM, van Dulmen AM, et al. Nursing assistants' behaviour during morning care: effects of the implementation of snoezelen, integrated in 24-hour dementia care. Journal of Advanced Nursing. Mar. 2006;53(6):656-68. Not mental health condition. [pmid: 16553674].
886 van Weert JC, van Dulmen AM, Spreeuwenberg PM, et al. Effects of snoezelen, integrated in 24 h dementia care, on nurse-patient communication during morning care. Patient Education & Counseling. Sep. 2005;58(3):312-26. Not primary care setting. [pmid: 16054329].
887 Vanderplasschen W, De Bourdeaudhuij I, Van Oost P. Co-ordination and continuity of care in substance abuse treatment. An evaluation study in Belgium. European Addiction Research. Jan. 2002;8(1):10-21. Not integrated care. [pmid: 11818689].
888 Ventegodt S, Clausen B, Omar HA, et al. Clinical holistic medicine: holistic sexology and acupressure through the vagina (Hippocratic pelvic massage). The scientific world journal. 2006;6:2066-79. Not mental health condition. [pmid: 17370003].
889 Ventura LA, Cassel CA, Jacoby JE, et al. Case management and recidivism of mentally ill persons released from jail. Psychiatric Services. Oct. 1998;49(10):1330-7. Not primary care setting. [pmid: 9779904].
890 Verhaak PF. Analysis of referrals of mental health problems by general practitioners. British Journal of General Practice. May. 1993;43(370):203-8. Not integrated care. [pmid: 8347388].
891 Verhaak PF, Tijhuis MA. Psychosocial problems in primary care: some results from the Dutch National Study of Morbidity and Interventions in General Practice. Social Science & Medicine. Jul. 1992;35(2):105-10. Not integrated care. [pmid: 1509299].
892 Vickrey BG, Mittman BS, Connor KI, et al. The effect of a disease management intervention on quality and outcomes of dementia care: a randomized, controlled trial.[see comment][summary for patients in Ann Intern Med. 2006 Nov 21;145(10):I31; PMID: 17116913]. Annals of Internal Medicine. Nov 21. 2006;145(10):713-26. Not integrated care. [pmid: 17116916].
893 Vines RF, Richards JC, Thomson DM, et al. Clinical psychology in general practice: a cohort study. Medical Journal of Australia. Jul 19. 2004;181(2):74-7. International. [pmid: 15257641].
894 Vitiello B. Research in child and adolescent psychopharmacology: Recent accomplishments and new challenges. Psychopharmacology. Mar. 2007;191(1):5-13. Not integrated care. [pmid: 16718480].
895 Von Korff M, Goldberg D. Improving outcomes in depression.[see comment]. BMJ. Oct 27. 2001;323(7319):948-9. Not on target, other publication type. [pmid: 11679372].
896 Von Korff M, Katon W, Lin EH, et al. Evaluation of psychiatric consultation-liaison in primary care settings. General Hospital Psychiatry. Mar. 1987;9(2):118-25. Not on target, other publication type. [pmid: 3569885].
897 Von Korff M, Lin EH, Fenton JJ, et al. Frequency and priority of pain patients' health care use. Clinical Journal of Pain. Jun. 2007;23(5):400-8. Not mental health condition. [pmid: 17515738].
898 Vostanis P, Anderson L, Window S. Evaluation of a family support service: short-term outcome. Clinical Child Psychology & Psychiatry. Oct. 2006;11(4):513-28. Not integrated care. [pmid: 17163221].
899 Wadland WC, Stoffelmayr B, Berger E, et al. Enhancing smoking cessation rates in primary care.[see comment]. Journal of Family Practice. Sep. 1999;48(9):711-8. Not mental health condition. [pmid: 10498078].
900 Waldorff FB, Rishoj S, Waldemar G. Identification and diagnostic evaluation of possible dementia in general practice. A prospective study Scandinavian. Journal of Primary Health Care. Dec. 2005;23(4):221-6. International.
901 Walker Z, Townsend J, Oakley L, et al. Health promotion for adolescents in primary care: randomised controlled trial. BMJ. Sep 7. 2002;325(7363):524-7. International. [pmid: 12217993].
902 Walters K, Buszewicz M, Raven P. An integrated model for teaching psychiatry in the community. Academic Medicine. May. 2001;76(5):563-4. International. [pmid: 11346617].
903 Wand T. Mental health liaison nursing in the emergency department: on-site expertise and enhanced coordination of care Australian Journal of Advanced Nursing 2004 Dec–2005 Feb; 22(2):25–31. Not primary care setting
904 Wand T, Fisher J. The mental health nurse practitioner in the emergency department: an Australian experience. International Journal of Mental Health Nursing. Sep. 2006;15(3):201-8. International. [pmid: 16916414].
905 Warner JP, King M, Blizard R, et al. Patient-held shared care records for individuals with mental illness. Randomised controlled evaluation. British Journal of Psychiatry. Oct. 2000;177:319-24. International. [pmid: 11116772].
906 Watts BV, Shiner B, Pomerantz A, et al. Outcomes of a quality improvement project integrating mental health into primary care. Quality & Safety in Health Care. Oct. 2007;16(5):378-81. Not included study design. [pmid: 17913780].
907 Webber V, Davies P, Pietroni P. Counselling in an inner city general practice: analysis of its use and uptake. British Journal of General Practice. Apr. 1994;44(381):175-8. Not integrated care. [pmid: 8185992].
908 Wells KB. Depression in general medical settings. Implications of three health policy studies for consultation-liaison psychiatry. Psychosomatics. May–Jun. 1994;35(3):279-96. Not on target, other publication type. [pmid: 8036257].
909 Wens J, Vermeire E, Royen PV, et al. GPs' perspectives of type 2 diabetes patients' adherence to treatment: A qualitative analysis of barriers and solutions. BMC Family Practice. May 12. 2005;6(1):20. Not integrated care. [pmid: 15890071].
910 Werner B, Reingold J. Expanding adult day care successfully Pride Institute. Journal of Long Term Home Health Care. 1993;12(4):27-35. Not primary care setting.
911 Weyerer S, Dilling H. Psychiatric and physical illness, sociodemographic characteristics, and the use of psychotropic drugs in the community: results from the Upper Bavarian Field Study. Journal of Clinical Epidemiology. 1991;44(3):303-11. Not integrated care. [pmid: 1999690].
912 Whiston S, Prendergast MJ, Williams SA. Sedation in primary dental care: an investigation in two districts of northern England. British Dental Journal. Apr 25. 1998;184(8):390-3. Not primary care setting. [pmid: 9604509].
913 White K, Holden E, Byng R, et al. Under/over-recruitment to mental health trials.[comment]. Acta Psychiatrica Scandinavica. Aug. 2007;116(2):158. International. [pmid: 17650285].
914 Whitfield M, Langan J, Russell O. Assessing general practitioners' care of adult patients with learning disability: case-control study. Quality in Health Care. Mar. 1996;5(1):31-5. Not mental health condition. [pmid: 10157270].
915 Whitford DL, Chan WS. A randomised controlled trial of a lengthened and multi-disciplinary consultation model in a socially deprived community: a study protocol. BMC Family Practice. 2007;8:38. International. [pmid: 17598899].
916 Whooley MA, Stone B, Soghikian K. Randomized trial of case-finding for depression in elderly primary care patients. Journal of General Internal Medicine. May. 2000;15(5):293-300. not integrated care. [pmid: 10840264].
917 Widmer RB, Cadoret RJ, North CS. Depression in family practice: some effects on spouses and children. Journal of Family Practice. Jan. 1980;10(1):45-51. Not integrated care. [pmid: 7350260].
918 Wileman L, May C, Chew-Graham CA. Medically unexplained symptoms and the problem of power in the primary care consultation: a qualitative study. Family Practice. Apr. 2002;19(2):178-82. Not integrated care. [pmid: 11906984].
919 Wilhelm K, Finch A, Kotze B, et al. The Green Card Clinic: overview of a brief patient-centred intervention following deliberate self-harm. Australasian Psychiatry. Feb. 2007;15(1):35-41. Not primary care setting. [pmid: 17464632].
920 Wilkinson G, Markus AC. PROQSY: a computerised technique for psychiatric case identification in general practice. British Journal of Psychiatry. Mar. 1989;154:378-82. Not integrated care. [pmid: 2688779].
921 Wilkinson G, Markus AC. Validation of a computerized assessment (PROQSY) of minor psychological morbidity by Relative Operating Characteristic analysis using a single GP's assessments as criterion measures. Psychological Medicine. Feb. 1989;19(1):225-31. Not integrated care. [pmid: 2657830].
922 Wilkinson G, Piccinelli M, Falloon I, et al. An evaluation of community-based psychiatric care for people with treated long-term mental illness. British Journal of Psychiatry. Jul. 1995;167(1):26-37. discussion 8–40. International. [pmid: 7551605].
923 Wilkinson G, Smeeton N, Skuse D, et al. Consultation for physical illnesses by patients diagnosed and treated for psychiatric disorders by a general practitioner: 20 year follow up study. BMJ. Sep 24. 1988;297(6651):776-8. International. [pmid: 3142546].
924 Williams J, Burwell S, Foy CG, et al. Addressing behavioral health issues during well child visits by pediatric residents. Clinical Pediatrics. Oct. 2006;45(8):734-40. Not included study design. [pmid: 16968959].
925 Williams JW Jr. Feedback to physicians plus telephone care management improved outcomes in primary care patients with depression. ACP Journal Club. Sep–Oct. 2000;133(2):73. International.
926 Williams N. Managing back pain in general practice—is osteopathy the new paradigm?. British Journal of General Practice. Oct. 1997;47(423):653-5. Not mental health condition. [pmid: 9474832].
927 Willmott Y. Prison nursing: the tension between custody and care. British Journal of Nursing. Mar 27–Apr 9. 1997;6(6):333-6. Not primary care setting. [pmid: 9155300].
928 Wilson A, McDonald P. Comparison of patient questionnaire, medical record, and audio tape in assessment of health promotion in general practice consultations. BMJ. Dec 3. 1994;309(6967):1483-5. Not integrated care. [pmid: 7804055].
929 Wilson BJ, Torrance N, Mollison J, et al. Improving the referral process for familial breast cancer genetic counselling: findings of three randomised controlled trials of two interventions Health Technology Assessment 2005; 9(3):iii–iv, ix–xi, 1–126. Not mental health condition
930 Wilson I. A pilot study to validate modification of the Duke University Severity of Illness scale to measure a family's burden of illness. Family Practice. Aug. 2004;21(4):443-6. Not integrated care. [pmid: 15249535].
931 Winefield HR, Turnbull DA, Seiboth C, et al. Evaluating a program of psychological interventions in primary health care: consumer distress, disability and service usage. Australian & New Zealand Journal of Public Health. Jun. 2007;31(3):264-9. International. [pmid: 17679246].
932 Wise TN. Commentary: psychiatry and primary care. General Hospital Psychiatry. Jul. 1985;7(3):202-4. Not on target, other publication type. [pmid: 4018574].
933 Wittink MN, Barg FK, Gallo JJ. Unwritten rules of talking to doctors about depression: integrating qualitative and quantitative methods. Annals of Family Medicine. Jul–Aug. 2006;4(4):302-9. Not integrated care. [pmid: 16868233].
934 Wolf FM, Miller JG, Gruppen LD, et al. Teaching skills for accessing and interpreting information from systematic reviews/meta-analyses, practice guidelines, and the Internet Proceedings/AMIA Annual Fall Symposium 1997:662–6. Not integrated care
935 Wong WM, Risner-Adler S, Beeler J, et al. Noncardiac chest pain: the role of the cardiologist—a national survey. Journal of Clinical Gastroenterology. Nov–Dec. 2005;39(10):858-62. Not mental health condition. [pmid: 16208108].
936 Wood K, Anderson J. The effect on hospital admissions of psychiatric case management involving general practitioners: preliminary results. Australian & New Zealand Journal of Psychiatry. Jun. 1995;29(2):223-9. Not primary care setting. [pmid: 7487784].
937 Woodend AK. Nurse led secondary prevention clinics improved health and decreased hospital admissions in patients with coronary heart disease. Evidence-Based Nursing. Jan. 1999;2(1):21. Not mental health condition.
938 Wright AF. Psychological distress: outcome and consultation rates in one general practice. Journal of the Royal College of General Practitioners. Dec. 1988;38(317):542-5. International. [pmid: 3267742].
939 Yager J, Linn LS, Leake B, et al. Initial clinical judgments by internists, family physicians, and psychiatrists in response to patient vignettes: II. General Hospital Psychiatry. May. 1986;8(3):152-8. Not integrated care. [pmid: 3710147].
940 Yawn BP, Wollan P, Gazzuola L, et al. Diagnosis and 10-year follow-up of a community-based hepatitis C cohort. Journal of Family Practice. Feb. 2002;51(2):135-40. Not mental health condition. [pmid: 11978211].
941 Yee EF, White RE, Murata GH, et al. Osteoporosis management in prostate cancer patients treated with androgen deprivation therapy. Journal of General Internal Medicine. Sep. 2007;22(9):1305-10. Not mental health condition. [pmid: 17634780].
942 Younes N, Gasquet I, Gaudebout P, et al. General Practitioners' opinions on their practice in mental health and their collaboration with mental health professionals. BMC Family Practice. May 2. 2005;6(1):18. International. [pmid: 15865624].
943 Younes N, Hardy-Bayle MC, Falissard B, et al. Differing mental health practice among general practitioners, private psychiatrists and public psychiatrists. BMC Public Health. 2005;5:104. Not integrated care. [pmid: 16212666].
944 Young TL, Ireson C. Effectiveness of school-based telehealth care in urban and rural elementary schools. Pediatrics. Nov. 2003;112(5):1088-94. Not primary care setting. [pmid: 14595051].
945 Zatzick DF, Roy-Byrne P, Russo JE, et al. Collaborative interventions for physically injured trauma survivors: a pilot randomized effectiveness trial. General Hospital Psychiatry. May–Jun. 2001;23(3):114-23. Not primary care setting. [pmid: 11427243].
946 Ziviani J, Lennox N, Allison H, et al. Meeting in the middle: improving communication in primary health care consultations with people with an intellectual disability. Journal of Intellectual & Developmental Disability. Sep. 2004;29(3):211-25. Not mental health condition.
947 Zun LS, Downey L. Pediatric health screening and referral in the ED. American Journal of Emergency Medicine. Oct. 2005;23(6):737-41. Not primary care setting. [pmid: 16182980].
948 Zweig RA, Siegel L, Hahn S, et al. Doctoral clinical geropsychology training in a primary care setting. Gerontology & Geriatrics Education. 2005;25(4):109-29. Medical education. [pmid: 16048878].

Appendixes cited in this report are available at http://www.ahrq.gov/downloads/pub/evidence/pdf/mhsapc/mhsapc.pdf