# Appendix E: Evidence Table

Project Name or 1^st^ Author, Year, Study Design | Study Aim | Study Period | Patient Population | Settings | Outcomes Measured
Depression Disorders
Fortney, 2007 ^1,^ ^2^ RCT Randomized by matched site | Assess telemedicine - based collaborative care vs. usual care to improve depression care at small clinics without on-site psychiatrists. | Recruitment 2003. Study period 12 months. | Current VA patients diagnosed with depression. 92% male, 75% white, mean age 59. Control N=218 Intervention N=177 | 7 rural VA community-based outpatient clinics with no on-site psychiatry or psychology in AK, MS, LA. | Depression symptoms, remission, treatment response, adherence. Physical, mental quality of life, wellbeing, and patient satisfaction. Model fidelity.
PRISM-E (for depression) ^3^ – ^5^ RCT Randomized by patient | Assess integrated vs. enhanced referral care for improving depression outcomes in elderly patients. | Recruitment March 2000 to March 2002. Study period 6 months | Elderly primary care patients: 31% female, 55% non-white, mean age 74 Integrated N=758 Referral N=773 | 10 practices with 34 urban, suburban, and rural clinics. 5 VA, 3 community health, 2 hospital networks in the Northeast, Miami, and Chicago | Depression symptoms, remission, MH QoL. Program use.
Geron, 2006 ^6^ RCT | Assess social worker care manager vs. usual care for depressed home-dwelling frail elderly | Study period 12 months. Recruitment period not completed. | Current patients over 65 years with 2 or more chronic medical conditions, ER visit or hospital admission in past 6 months | An MCO urban primary care clinic. | Depression symptoms, satisfaction, QoL, adverse health outcomes, physical function, utilization, cost
Grypma, 2006 ^7^ Cohort | Assess adapted version of IMPACT post trial vs. usual care on depression care for adults. | Study period 12 months. IMPACT study period 1999-2001. Post-trial data from 2002-2004. | Current adult patients. 8.4% male, average age 63, 63% above 60 years RCT controls N=116 Post-study intervention N=95 | 2 Kaiser Permanente practices in San Diego area | Depression symptoms, utilization
IMPACT ^8^ – ^12^ RCT Randomized by patient | Assess collaborative care vs. usual care on depression care for elderly. | Recruitment July 1999 to August 2000. Intervention 12 months. Study period 2 years. | Current patients 60+ years old with depression. 65% female, 77% white, Control N=895 Intervention N=906 | 7 national sites in Indiana, Texas, Washington, and California. Rural and urban. Group and academic practices, and VA. | Depression symptoms, treatment response, remission, patient self-efficacy, function and QoL, satisfaction, antidepression medication use, treatment utilization
Clarke, 2005 ^13^ RCT Randomized by patient | Assess collaborative care with CBT vs. usual care for depressed HMO pediatric primary care patients. | Recruitment March 2000 to November 2001. Study period 1 year. | Pediatric patients age 12–18 years old in a current major depression episode. Average age 15, 77% female, 14% non-white. Control N=75 Intervention N=77 | HMO pediatric clinic in Portland, OR, part of Kaiser Permanente | Depression symptoms, relapse, QoL, satisfaction, utilization
PROSPECT ^14^ – ^16^ RCT Randomization by matched sites | Assess guideline based depression recognition and treatment program vs. usual care for elderly patients to prevent and reduce suicidal behavior | Recruitment May 1999 to August 2001. Study period 2 years | English speaking patients over 60 years with major depression. 31% above age 75, 72% female, 32% non-white. Control N=278 Intervention N=320 | 18 clinics in New York, Pennsylvania, and Pittsburgh. Group, university affiliated, and solo practices in urban, suburban, and rural locations. | Depression symptoms, treatment response, and remission, utilization
Pathways ^17,^ ^18^ RCT Randomized by patient | Assess collaborative care vs. usual care for adult diabetes patients with depression | Recruitment April 2001 to May 2002. Intervention 12 months. Study period 2 years | English speaking adult diabetes patients with major depression. Average age 58, 65% female, 81% white. Control N=165 Intervention N-165 | 9 HMO clinics within 40 mile radius of Seattle. | Depression symptoms, diabetes outcomes and self-care, functional and QoL, adherence and utilization, cost-effectiveness.
RESPECT-D ^19,^ ^20^ RCT | Assess evidence-based model of depression management vs. usual care for adult patients with depression | Recruitment February 2002 to February 2003. Patient study period 6 months. | English speaking patients 18 years or older starting treatment for major depression. Average age 42, 80% female, 17% non-white. Control N=181 Intervention N=224 | 3 medical groups and 2 health plans across U.S., each with at least 10 PC practices and established QI programs. 60 practices, matched and randomized. | Depression symptoms, treatment response, remission, utilization
Simon, 2004 ^21^ RCT Randomized by patient | Assess telephone care management and telephone care management plus psychotherapy vs. usual care for adult patients with depression. | Recruitment November 2000 to May 2002. Study period 6 months. | Adult patients beginning antidepressant treatment. Average age 44, 74% female, 79% white Control N=195 Telephone care N=207 Telephone care + psychotherapy N=198 | 7 urban and suburban HMO clinics in Washington State. | Depression symptoms, remission, adequate pharmacotherapy.
Adler, 2004 ^22,^ ^23^ RCT Randomized by patient | Assess pharmacist adherence management vs. usual care for adult patients with depression. | Study period 6 months. Recruitment not reported. | English speaking adults with major depression. Average age 42, 72% female, 72% white. Control N=265 Intervention N=268 | 9 group practice clinics in Boston area, with 5 clinics at an academic medical center. | Depression symptoms, antidepressant utilization and adherence.
Finley, 2004 ^24^ RCT Randomized by patient | Assess collaborative care with pharmacist care manager vs. usual care for adults with depression. | Study period 6 months. Recruitment not reported | Adult patients beginning antidepressant treatment. Average age 54, 85% female. Control N=50 Intervention N=75 | HMO clinic in San Rafael, CA. | Depression symptoms, treatment response, remission, change in disability, adherence and utilization, cost.
Swindle, 2003 ^25^ RCT Randomized by patient | Assess collaborative care with MH clinical nurse care manager vs. usual care for veterans with depression | Study period 12 months. Recruitment not reported. | Community dwelling adult patients with depression. 97% male, 85% white. Control N=134 Treatment N=134 | 2 Indianapolis VA clinics, randomized by site. | Depression symptoms, utilization, cost.
Partners in Care ^26^ – ^30^ RCT Randomized by site | Assess quality improvements in medication management and therapy vs. usual care for adults with depression | Intervention 6 months. Study period 2 years. Recruitment not reported. | English or Spanish speaking adult patients with depression. Average age 44, 71% female, 30% Hispanic. Control N=430 QI Meds N=405 QI Therapy N=464 | 6 MCOs representing geographically diverse regions in U.S., with 46 clinics. | Depression symptoms, QoL, employment, utilization, overall poor outcome (constructed measure)
Datto, 2003 ^31^ RCT Randomized across sites | Assess telephone-based depression management for acute phase depression vs. usual care for adult patients. | Study period 16 weeks. Recruitment not reported. | Patients with depression. Average age 48, 61% female, 80% white. Control N=31 Intervention N=30 | 35 urban and suburban clinics in Pennsylvania. | Depression symptoms, QoL, clinician and patient adherence.
Hedrick, 2003 ^32^ RCT Randomized across sites | Assess collaborative care vs. usual consult-liaison care for VA patients with depression. | Study period 9 months. Recruitment January 1998 to March 1999. | Current patient with major depression, dysthymia, or both. Average age 57, 95% male, 80% white. Control N=186 Intervention N=168 | 4 clinics in Seattle division of VA-Puget Sound. | Depression symptoms, treatment response, remission, QoL, medication utilization.
Katon, 1995 ^33^ RCT Randomized by patient | Assess collaborative care vs. usual care for adult patients with depression. | Study period 12 months. Intervention period up to 9 months. Recruitment not reported. | English speaking, current adult patients beginning antidepressants. Average age 48, 76% female. Control N=109 Intervention N=108 | Northgate Medical Center, Group Health Cooperative HMO in western Washington state, a family physician clinic. | Depression symptoms, disability, medication adherence, satisfaction, utilization
Katon, 1999 ^34^ RCT Randomized by patient | Assess stepped collaborative care vs. usual care for adult patients with depression. | Study period 6 months. Recruitment not reported. | English speaking, current adult patients beginning antidepressants. Average age 47, 75% female, 80% white. Control N=114 Intervention N=114 | 4 Group Health Cooperative HMO clinics in Seattle area. | Depression symptoms, disability, medication adherence, costs
Katon, 1996 ^35^ RCT Randomized by patient | Assess collaborative care vs. usual care for adult patients with depression. | Study period 6 months. Recruitment not reported. | English speaking, current adult patients beginning antidepressants. Average age 46, 74% female, 87% white. Control N=76 Intervention N=77 | Northgate Medical Center, Group Health Cooperative HMO in western Washington state, a family physician clinic. | Depression symptoms, disability, medication adherence, costs
Katon, 2001 ^36,^ ^37^ RCT Randomized by patient | Assess collaborative care vs. usual care for adult patients at risk for depression relapse | Study period 12 months. Recruitment not reported. | English speaking, current adult patients beginning antidepressants. Average age 46, 73% female, 90% white. Control N=192 Intervention N=194 | 4 Group Health Cooperative HMO clinics in Seattle area. | Depression symptoms, depression relapse, medication adherence
Capoccia 2004 ^38,^ ^39^ RCT Randomized by patient | Assess pharmacist based collaborative care vs. usual care for adults with depression | Recruitment from November 1999 to March 2001. Study period 12 months. | English speaking current adult patients beginning antidepressants. Average age 39, 57% female, 22% non-white. Control N=33 Intervention N=41 | Academic family practice clinic in Seattle. | Depression symptoms, QoL, medication adherence, utilization, cost.
Tutty, 2000 ^40^ Cohort | Assess telephone counseling and medication monitoring for adult patients with depression. | Study period 6 months. Recruitment not reported. | Adult patients beginning antidepressants. Average age 47, 69% female. Control N=94 Intervention N=28 | One Group Health Cooperative clinic in Olympia. | Depression symptoms, treatment response, remission, adequate dosage.
Hunkeler 2000 ^41^ RCT Randomized by site | Assess nurse telehealth care vs. usual care for adults with depression. | Study period 6 months. Recruitment not reported. | English speaking adults with SSRI prescription for depression. About 70% female, 37% non-white. Control N=123 Intervention N=179 | 2 Kaiser Permanente clinics in northern CA. | Depression symptoms, treatment response, QoL, adherence.
QuEST ^42^ – ^44^ RCT Randomized by matched site | Assess guideline based depression treatment program vs. usual care for adult patients with depression. | Recruitment from April 1996 to September 1997. Study period 2 years. | English reading current adult patients with depression. Average age 43, 84% female, 16% non-white. Control N=240 Intervention N=239 | 12 practices across U.S. Urban and rural. | Depression symptoms, QoL, guideline concordant care.
Simon, 2000 ^45^ RCT Randomized by patients | Assess feedback only or feedback plus care management vs. usual care for adult patients with depression. | Study period 6 months. Intervention period 4 months. Recruitment period not reported. | Current adult patients newly prescribed antidepressants. Average age 46 years, 72% female. Control N=196 Feedback only N=221 FB and care mgmt N=196 | 5 HMO primary care clinics in Washington state | Depression symptoms, treatment response, remission, adequate dosage, cost
Hilty, 2007 ^46^ RCT Randomized by patient | Assess usual care depression management with telepsychiatric and PCP training vs. usual care depression management for adult patients with depression. | Study period 1 year. 2 year recruitment, period not reported. | English speaking current adult patients with depression willing to take antidepressants. Median age 46, 80% female, 10% non-white. Control N=41 Intervention N=52 | 8 rural primary care clinics, average 140 miles from UC Davis Medical Center. | Depression symptoms, functioning and QoL, satisfaction.
Katzelnick, 2000 ^47^ RCT Randomization across sites by physician practices | Assess depression management vs. usual care for high utilizers with depression, not in active treatment | Study period 12 months. Recruitment period not reported. | Current adult patients above 85^th^ percentile in utilization for previous 2 years. Average age 45, 77% female, 83% white Control N=189 Intervention N=218 | 3 HMOs in the Midwest, Northwest and New England regions, 163 primary care practices. | Depression symptoms, treatment response, remission, functioning and QoL, utilization
Anxiety Disorders
Roy-Byrne, 2001 ^48^ RCT Randomized by patient | Assess collaborative care vs. usual care for adult patients with panic disorder. | Study period 12 months. Recruitment not reported. | English speaking adult patients with at least one panic attack in last month. Average age 41, 57% female, 67% white. Control N=58 Intervention N=57 | 3 urban and suburban group practice clinics in Seattle area, 2 are university associated. | Panic, anxiety, and depression symptoms, treatment response, remission, QoL, appropriate medication and dosage, adherence.
CCAP ^49,^ ^50^ RCT Randomized by patient, stratified within site | Assess collaborative care vs. usual care for adults with panic disorder. | Recruitment March 2000 to March 2002. Study period 1 year. | English speaking adult patients with at least one panic attack within last week. Average age 41, 67% female, 66% white Control N=113 Intervention N=119 | University affiliated primary care clinics in Seattle, San Diego, and Los Angeles | Remission, treatment response, anxiety sensitivity, depression symptoms, QoL and functional disability, utilization
CALM ^51^ RCT Randomized across sites | Assess collaborative care vs. usual care for adult patients with anxiety disorders, including GAD, PTSD, PD, and SAD | Study period 18 months. Recruitment not complete | English speaking adult current patients with GAD, PTSD, PD and SAD, N to be1040, 260 at each site | Seattle, WA, Los Angeles and San Diego, CA, and Little Rock, AK | Anxiety disorder symptoms, functioning and QoL, satisfaction, utilization. Design only. No results yet
Rollman, 2005 ^52,^ ^53^ RCT Randomized by patients | Assess telephone-based collaborative care vs. usual care for adult anxiety and panic disorder patients. | Recruitment July 2000 to April 2002. Study period 12 months | English speaking, adult current patients with anxiety disorders. Average age 44 years, 81% female, 95% white. Control N=75 Intervention N=116 | 13 PCPs in Pittsburgh area, urban academic, suburban, and rural. | Anxiety disorder symptoms, depression symptoms, QoL, utilization, employment status
Price, 2000 ^54^ Matched Cohort | Assess integrated care vs. usual care for adult patients with generalized anxiety disorder (GAD) and GAD secondary to depression. | Study period 6 months. Recruitment not reported | English speaking, adult current patients with GAD. Mean age 49 years, 80% female, 86% white. Control N=111 Intervention N=113 | Kaiser Permanente clinics in Westminster, CO. Intervention patients family practice, control patients internal medicine | Anxiety symptoms, satisfaction
Other
Katon, 1992 ^55^ RCT Randomized by patients, stratified by physician and blocked | Assess effect of psychiatric consultation vs. usual care for distressed high utilizers of medical care. | Study period 12 months. Recruitment not reported. | Top 10% adult ambulatory care utilizers of appropriate age group with psychiatric distress. Average age 47, 61% female. Control N=127 Intervention N=124 | 2 primary care clinics of Group Health Cooperative of Puget Sound. | Psychiatric distress, functional disability, utilization, use of and adherence to antidepressants
Epstein, 2007 ^56^ RCT Randomized by pediatricians | Assess collaborative care consultative service for titration and monitoring vs. usual care to improve ADHD care. | Study period 1 year. Recruitment not reported. | 1^st^ through 5^th^ grade children with ADHD Control N=215 Intervention N=162 | 12 community-based pediatric practices without onsite psychiatry or psychologist. | ADHD symptoms. Titration trials, medication management, dosage, adherence
PRISM-E (for at-risk alcohol use) ^4,^ ^5,^ ^57^ RCT Randomized by patients | Assess integrated vs. enhanced referral care for managing at-risk alcohol use in elderly patients | Recruitment March 2000 to March 2002. Study period 6 months (on-going) | Elderly primary care patients. 92% male, 70% white, mean age 72 Intervention N=280 Referral N=280 | 9 practices with 34 urban, suburban, and rural clinics. 5 VA, 2 community health, 2 hospital networks in the Northeast, Miami, and Chicago | Drinking severity, MH QoL, Program use.
Backward Integration
Weisner, 2001 ^58,^ ^59^ RCT Randomized by patients | Assess integrated vs. usual care for medical and substance abuse care | Recruitment April 1997 to December 1998. Study period 6 months | Adult patients admitted to a chemical dependency program. Mean age 37, 55% male, 74% white. Control N=307 Intervention N=285 | Kaiser Permanente's Chemical Dependency Recovery Program, southern CA | Abstinence, treatment utilization. No primary care outcomes
Druss, 2001 ^60^ RCT Randomized by patients Willenbring, 1999 ^61^ RCT Randomized by patients | Assess integrated medical health care vs. usual care for patients with serious mental illness | Study period 12 months. Recruitment not reported. | VA mental health patients without a current primary care provider. Mean age 45, 99% male, 70% white Control N=61 Intervention N=59 | West Haven, CT, VAMC | Utilization, quality of preventive care, satisfaction, physical and mental health status, costs
Assess integrated outpatient treatment vs. usual care for alcohol-related medically ill alcohol abuse patients | Study period 2 years. Recruitment period not reported. | VA patients with current alcohol abuse behavior and alcohol-related medical illness. Mean age=55.1 Control N=53 Intervention N=48 | Minneapolis, MN VA medical center | Drinking severity, quality of life, utilization

## References for Appendix E

1 Fortney JC, Pyne JM, Edlund MJ, et al. A randomized trial of telemedicine-based collaborative care for depression. Journal of General Internal Medicine. Aug. 2007;22(8):1086-93. [pmid: 17492326].
2 Fortney JC, Pyne JM, Edlund MJ, et al. Design and implementation of the telemedicine-enhanced antidepressant management study. General Hospital Psychiatry. Jan–Feb. 2006;28(1):18-26. [pmid: 16377361].
3 Krahn DD, Bartels SJ, Coakley E, et al. PRISM-E: comparison of integrated care and enhanced specialty referral models in depression outcomes. Psychiatric Services. Jul. 2006;57(7):946-53. [pmid: 16816278].
4 Bartels SJ, Coakley EH, Zubritsky C, et al. Improving access to geriatric mental health services: a randomized trial comparing treatment engagement with integrated versus enhanced referral care for depression, anxiety, and at-risk alcohol use.[see comment]. American Journal of Psychiatry. Aug. 2004;161(8):1455-62. [pmid: 15285973].
5 Levkoff SE, Chen H, Coakley E, et al. Design and sample characteristics of the PRISM-E multisite randomized trial to improve behavioral health care for the elderly. Journal of Aging & Health. Feb. 2004;16(1):3-27. [pmid: 14979308].
6 Geron SM, Keefe B. Moving evidence-based interventions to populations: a case study using social workers in primary care. Home Health Care Services Quarterly. 2006;25(12):95-113. [pmid: 16803740].
7 Grypma L, Haverkamp R, Little S, et al. Taking an evidence-based model of depression care from research to practice: making lemonade out of depression.[see comment]. General Hospital Psychiatry. Mar–Apr. 2006;28(2):101-7. [pmid: 16516059].
8 Hunkeler EM, Katon W, Tang L, et al. Long term outcomes from the IMPACT randomised trial for depressed elderly patients in primary care.[see comment]. BMJ. Feb 4. 2006;332(7536):259-63. [pmid: 16428253].
9 Callahan CM, Kroenke K, Counsell SR, et al. Treatment of depression improves physical functioning in older adults.[see comment]. Journal of the American Geriatrics Society. Mar. 2005;53(3):367-73. [pmid: 15743276].
10 Unutzer J, Tang L, Oishi S, et al. Reducing suicidal ideation in depressed older primary care patients.[see comment]. Journal of the American Geriatrics Society. Oct. 2006;54(10):1550-6. [pmid: 17038073].
11 Unutzer J, Katon W, Callahan CM, et al. Collaborative care management of late-life depression in the primary care setting: a randomized controlled trial.[see comment]. JAMA. Dec 11. 2002;288(22):2836-45. [pmid: 12472325].
12 Unutzer J, Katon W, Williams JW Jr, et al. Improving primary care for depression in late life: the design of a multicenter randomized trial. Medical Care. Aug. 2001;39(8):785-99. [pmid: 11468498].
13 Clarke G, Debar L, Lynch F, et al. A randomized effectiveness trial of brief cognitive-behavioral therapy for depressed adolescents receiving antidepressant medication. Journal of the American Academy of Child & Adolescent Psychiatry. Sep. 2005;44(9):888-98. [pmid: 16113617].
14 Alexopoulos GS, Katz IR, Bruce ML, et al. Remission in depressed geriatric primary care patients: a report from the PROSPECT study. American Journal of Psychiatry. Apr. 2005;162(4):718-24. [pmid: 15800144].
15 Bruce M, Ten Have T, Reynolds Cr, et al. Reducing suicidal ideation and depressive symptoms in depressed older primary care patients: a randomized controlled trial. JAMA. Mar 3. 2004;291(9):1081-91. [pmid: 14996777].
16 Bruce ML, Pearson JL. Designing an intervention to prevent suicide: PROSPECT (Prevention of Suicide in Primary Care Elderly: Collaborative Trial). Dialogues in Clinical Neuroscience. 1999;1(2):100-12. [pmid: 22033641].
17 Katon WJ, Von Korff M, Lin EH, et al. The Pathways Study: a randomized trial of collaborative care in patients with diabetes and depression.[see comment]. Archives of General Psychiatry. Oct. 2004;61(10):1042-9. [pmid: 15466678].
18 Katon W, Von Korff M, Lin E, et al. Improving primary care treatment of depression among patients with diabetes mellitus: the design of the pathways study. General Hospital Psychiatry. May–Jun. 2003;25(3):158-68. [pmid: 12748028].
19 Dietrich AJ, Oxman TE, Williams JW Jr, et al. Re-engineering systems for the treatment of depression in primary care: cluster randomised controlled trial.[see comment]. BMJ. Sep 11. 2004;329(7466):602. [pmid: 15345600].
20 Oxman T, Dietrich A, Williams JJ, et al. A three-component model for reengineering systems for the treatment of depression in primary care. Psychosomatics. Nov–Dec. 2002;43(6):441-50. [pmid: 12444226].
21 Simon GE, Ludman EJ, Tutty S, et al. Telephone psychotherapy and telephone care management for primary care patients starting antidepressant treatment: a randomized controlled trial.[see comment]. JAMA. Aug 25. 2004;292(8):935-42. [pmid: 15328325].
22 Adler DA, Bungay KM, Wilson IB, et al. The impact of a pharmacist intervention on 6-month outcomes in depressed primary care patients. General Hospital Psychiatry. May–Jun. 2004;26(3):199-209. [pmid: 15121348].
23 Bungay KM, Adler DA, Rogers WH, et al. Description of a clinical pharmacist intervention administered to primary care patients with depression. General Hospital Psychiatry. May–Jun. 2004;26(3):210-8. [pmid: 15121349].
24 Finley PR, Rens HR, Pont JT, et al. Impact of a collaborative care model on depression in a primary care setting: a randomized controlled trial. Pharmacotherapy. Sep. 2003;23(9):1175-85. [pmid: 14524649].
25 Swindle RW, Rao JK, Helmy A, et al. Integrating clinical nurse specialists into the treatment of primary care patients with depression. International Journal of Psychiatry in Medicine. 2003;33(1):17-37. [pmid: 12906341].
26 Jaycox LH, Miranda J, Meredith LS, et al. Impact of a primary care quality improvement intervention on use of psychotherapy for depression. Mental Health Services Research. Jun. 2003;5(2):109-20. [pmid: 12801074].
27 Sherbourne CD, Wells KB, Duan N, et al. Long-term effectiveness of disseminating quality improvement for depression in primary care. Archives of General Psychiatry. Jul. 2001;58(7):696-703. [pmid: 11448378].
28 Schoenbaum M, Unutzer J, McCaffrey D, et al. The effects of primary care depression treatment on patients' clinical status and employment. Health Services Research. Oct. 2002;37(5):1145-58. [pmid: 12479490].
29 Wells K. The design of Partners in Care: evaluating the cost-effectiveness of improving care for depression in primary care. Social Psychiatry & Psychiatric Epidemiology. Jan. 1999;34(1):20-9. [pmid: 10073117].
30 Wells K, Sherbourne C, Schoenbaum M, et al. Impact of disseminating quality improvement programs for depression in managed primary care: a randomized controlled trial. JAMA. Jan 12. 2000;283(2):212-20. [pmid: 10634337].
31 Datto CJ, Thompson R, Horowitz D, et al. The pilot study of a telephone disease management program for depression. General Hospital Psychiatry. May–Jun. 2003;25(3):169-77. [pmid: 12748029].
32 Hedrick SC, Chaney EF, Felker B, et al. Effectiveness of collaborative care depression treatment in Veterans' Affairs primary care.[see comment]. Journal of General Internal Medicine. Jan. 2003;18(1):9-16. [pmid: 12534758].
33 Katon W, Von Korff M, Lin E, et al. Collaborative management to achieve depression treatment guidelines. Journal of Clinical Psychiatry. 1997;58(Suppl 1):20-3. [pmid: 9054905].
34 Katon W, Von Korff M, Lin E, et al. Stepped collaborative care for primary care patients with persistent symptoms of depression: a randomized trial. Archives of General Psychiatry. Dec. 1999;56(12):1109-15. [pmid: 10591288].
35 Katon W, Robinson P, Von Korff M, et al. A multifaceted intervention to improve treatment of depression in primary care. Archives of General Psychiatry. Oct. 1996;53(10):924-32. [pmid: 8857869].
36 Katon W, Rutter C, Ludman EJ, et al. A randomized trial of relapse prevention of depression in primary care. Archives of General Psychiatry. Mar. 2001;58(3):241-7. [pmid: 11231831].
37 Ludman E, Von Korff M, Katon W, et al. The design, implementation, and acceptance of a primary care-based intervention to prevent depression relapse. International Journal of Psychiatry in Medicine. 2000;30(3):229-45. [pmid: 11209991].
38 Boudreau DM, Capoccia KL, Sullivan SD, et al. Collaborative care model to improve outcomes in major depression. Annals of Pharmacotherapy. Apr. 2002;36(4):585-91. [pmid: 11918503].
39 Capoccia KL, Boudreau DM, Blough DK, et al. Randomized trial of pharmacist interventions to improve depression care and outcomes in primary care. American Journal of Health-System Pharmacy. Feb 15. 2004;61(4):364-72. [pmid: 15011764].
40 Tutty S, Simon G, Ludman E. Telephone counseling as an adjunct to antidepressant treatment in the primary care system. A pilot study.[see comment]. Effective Clinical Practice. Jul–Aug. 2000;3(4):170-8. [pmid: 11183432].
41 Hunkeler EM, Meresman JF, Hargreaves WA, et al. Efficacy of nurse telehealth care and peer support in augmenting treatment of depression in primary care [see comment][comment]. Archives of Family Medicine. Aug. 2000;9(8):700-8. [pmid: 10927707].
42 Rost K, Nutting PA, Smith J, et al. Designing and implementing a primary care intervention trial to improve the quality and outcome of care for major depression. General Hospital Psychiatry. Mar–Apr. 2000;22(2):66-77. [pmid: 10822094].
43 Rost K, Nutting P, Smith JL, et al. Managing depression as a chronic disease: a randomised trial of ongoing treatment in primary care. BMJ. Oct 26. 2002;325(7370):934-7. [pmid: 12399343].
44 Rost K, Nutting P, Smith JL, et al. Improving depression outcomes in community primary care practice: a randomized trial of the QuEST intervention. Quality Enhancement by Strategic Teaming. Journal of General Internal Me. Mar. 2002;16(3):143-9.
45 Simon G, VonKorff M, Rutter C, et al. Randomised trial of monitoring, feedback, and management of care by telephone to improve treatment of depression in primary care.[see comment]. BMJ. Feb 26. 2000;320(7234):550-4. [pmid: 10688563].
46 Hilty DM, Marks S, Wegeland J, et al. A randomized, controlled trial of disease management modules, including telepsychiatric care, for depression in rural primary care. Psychiatry. Feb. 2007;4(2):58-65. [pmid: 20805900].
47 Katzelnick D, Simon G, Pearson S, et al. Randomized trial of a depression management program in high utilizers of medical care.[see comment]. Archives of Family Medicine. Apr. 2000;9(4):345-51. [pmid: 10776363].
48 Roy-Byrne PP, Katon W, Cowley DS, et al. A randomized effectiveness trial of collaborative care for patients with panic disorder in primary care.[see comment]. Archives of General Psychiatry. Sep. 2001;58(9):869-76. [pmid: 11545671].
49 Roy-Byrne P, Stein MB, Russo J, et al. Medical illness and response to treatment in primary care panic disorder. General Hospital Psychiatry. Jul–Aug. 2005;27(4):237-43. [pmid: 15993254].
50 Roy-Byrne PP, Craske MG, Stein MB, et al. A randomized effectiveness trial of cognitive-behavioral therapy and medication for primary care panic disorder.[see comment]. Archives of General Psychiatry. Mar. 2005;62(3):290-8. [pmid: 15753242].
51 Sullivan G, Craske MG, Sherbourne C, et al. Design of the Coordinated Anxiety Learning and Management study: Innovations in collaborative care for anxiety disorders. General Hospital Psychiatry. Sep–Oct. 2007;29(5):379-87. [pmid: 17888803].
52 Rollman BL, Belnap BH, Mazumdar S, et al. A randomized trial to improve the quality of treatment for panic and generalized anxiety disorders in primary care. Archives of General Psychiatry. Dec. 2005;62(12):1332-41. [pmid: 16330721].
53 Rollman BL, Herbeck Belnap B, Reynolds CF, et al. A contemporary protocol to assist primary care physicians in the treatment of panic and generalized anxiety disorders. General Hospital Psychiatry. Mar–Apr. 2003;25(2):74-82. [pmid: 12676419].
54 Price D, Beck A, Nimmer C, et al. The treatment of anxiety disorders in a primary care. HMO setting Psychiatric Quarterly. 2000;71(1):31-45. [pmid: 10736815].
55 Katon W, Von Korff M, Lin E, et al. A randomized trial of psychiatric consultation with distressed high utilizers. General Hospital Psychiatry. Mar. 1992;14(2):86-98. [pmid: 1592254].
56 Epstein JN, Rabiner D, Johnson DE, et al. Improving attention-deficit/hyperactivity disorder treatment outcomes through use of a collaborative consultation treatment service by community-based pediatricians: a cluster randomized trial. Archives of Pediatrics & Adolescent Medicine. Sep. 2007;161(9):835-40. [pmid: 17768282].
57 Oslin DW, Grantham S, Coakley E, et al. PRISM-E: comparison of integrated care and enhanced specialty referral in managing at-risk alcohol use.[erratum appears in Psychiatr Serv 2006 Oct;57(10):1492 Note: Olsen, Ed [added]; Kirchner, JoAnn E [added]; Levkoff, Sue [added]]. Psychiatric Services. Jul. 2006;57(7):954-8. [pmid: 16816279].
58 Parthasarathy S, Mertens J, Moore C, et al. Utilization and cost impact of integrating substance abuse treatment and primary care. Medical Care. Mar. 2003;41(3):357-67. [pmid: 12618639].
59 Weisner C, Mertens J, Parthasarathy S, et al. Integrating primary medical care with addiction treatment: a randomized controlled trial.[see comment]. JAMA. Oct 10. 2001;286(14):1715-23. [pmid: 11594896].
60 Druss BG, Rohrbaugh RM, Levinson CM, et al. Integrated medical care for patients with serious psychiatric illness: a randomized trial.[see comment]. Archives of General Psychiatry. Sep. 2001;58(9):861-8. [pmid: 11545670].
61 Willenbring M, Olson D. A randomized trial of integrated outpatient treatment for medically ill alcoholic men. Archives of Internal Medicine. Sep 13. 1999;159(16):1946-52. [pmid: 10493326].