# Appendix D: Patient Inclusion and Exclusion Criteria

Project Name or Author, Year, Study Design | Inclusion Criteria | Exclusion Criteria
Depression Disorders
Fortney, 2007 ^1,^ ^2^ | Current VA patients diagnosed with depression. 92% male, 75% white, mean age 59, Control N=218; Intervention N=177 | Schizophrenia, current suicide ideation, recent bereavement, pregnancy, a court-appointed guardian, substance dependence, bipolar disorder, cognitive impairment, or receiving specialty mental health treatment.
PRISM-E (for depression) ^3^ – ^5^ | Elderly primary care patients. 31% female, 55% non-white, mean age 74, Integrated N=758; Referral N=773 | Already received mental health/substance abuse treatment in the preceding 3 months and patients with severe cognitive impairment (≥16 on the Brief Orientation Memory Concentration Test), positive assessment on the Mini-International neuropsychiatric Interview for psychosis, mania, or hypomania
Geron, 2006 ^6^ | Current patients over 65 years with 2 or more chronic medical conditions, ER visit or hospital admission in past 6 months | N/A
Grypma, 2006 ^7^ | Current adult patients. 8.4% male, average age 63, 63% above 60 years, RCT controls N=116, Post-study intervention N=95 | N/A
IMPACT ^8^ – ^12^ | Current patients 60+ years old with depression. 65% female, 77% white, Control N=895, Intervention N=906 | Drinking problems, bipolar disorder or psychosis, severe cognitive impairment, acute risk of suicide, or ongoing psychiatric treatment
Clarke, 2005 ^13^ | Pediatric patients ages 12–18 years old in a current major depression episode. Average age 15, 77% female, 14% non-white. Control N=75, Intervention N=77 | Schizophrenia or significant developmental/intellectual disability
PROSPECT ^14^ – ^16^ | English speaking patients over 60 years with major depression. 31% above age 75, 72% female, 32% non-white. | Suicidal ideation, not English speaking, score ≤17 on the Mini-Mental State Examination
Pathways ^17,^ ^18^ | English speaking adult diabetes patients with major depression. Average age 58, 65% female, 81% white. | Currently in care with a psychiatrist; a diagnosis based on GHC's automated diagnostic data of bipolar disorder or schizophrenia; use of antipsychotic or mood stabilizer medication based on GHC's automated pharmacy data; and mental confusion on interview or significant dementia; SCL<1.1.
RESPECT-D ^19,^ ^20^ | English speaking patients 18 years or older starting treatment for major depression. Average age 42, 80% female, 17% non-white. | Unobtainable for an evaluation interview within 14 days of their index primary care visit, pregnant, suicidal thoughts, schizophrenia, bipolar disorder, post-traumatic stress disorder, substance misuse disorder
Simon, 2004 ^21^ | Adult patients beginning antidepressant treatment. Average age 44, 74% female, 79% white | Current alcoholism, bipolar disorder, and/or psychotic disorders.
Adler, 2004 ^22,^ ^23^ | English speaking adults with major depression. Average age 42, 72% female, 72% white. | Current alcoholism, bipolar disorder, and/or psychotic disorders. (Lifetime alcoholism or psychiatric conditions not excluded)
Finley, 2004 ^24^ | Adult patients beginning antidepressant treatment. Average age 54, 85% female. | Antidepressant use during the preceding 6 months; concurrent psychiatric or psychologic treatment; mania or bipolar disorder; psychotic symptoms; eminent suicidality; active substance abuse or dependence
Swindle, 2003 ^25^ | Community dwelling adult patients with depression dysthymia, or partially remitted major depression using PRIME-MD structured diagnostic interview. 97% male, 85% white. Control N=134, Treatment N=134 | Incompetent for interview: active psychosis, dementia documented in medical chart; residents of a nursing home; actively suicidal; seen in a VAMC mental health program; active cocaine or opiate abusers; bipolar disorder; terminally ill.
Partners in Care ^26^ – ^30^ | English or Spanish speaking adult patients with depression. Average age 44, 71% female, 30% Hispanic. Control N=430, QI Meds N=405, QI Therapy N=464 | Pregnant; mania or recent alcohol abuse; not insured by a plan or public-pay arrangement; <18 years; did not speak English or Spanish
Datto, 2003 ^31^ | Patients with depression. Average age 48, 61% female, 80% white. Control N=31, Intervention N=30 | Suicidal risks, ongoing substance abuse problems, current psychotic symptoms, bipolar affective disorder
Hedrick, 2003 ^32^ | Current patient with major depression, dysthymia, or both. Average age 57, 95% male, 80% white. Control N=186, Intervention N=168 | Recent visit to a mental health specialty clinic or scheduled a future appointment, required treatment for substance abuse or posttraumatic stress disorder prior to initiating depression treatment; acute suicidality, psychosis, or other condition requiring immediate treatment
Katon, 1995 ^33^ | English speaking, current adult patients beginning antidepressants. Average age 48, 76% female. Control N=109, Intervention N=108 | Current alcohol abuse; current psychotic symptoms or serious suicidal ideation or plan; dementia; pregnancy; terminal illness; limited command of English; plan to disenroll from the GHC insurance plan within the next 12 months
Katon, 1999 ^34^ | English speaking, current adult patients beginning antidepressants. Average age 47, 75% female, 80% white. Control N=114, Intervention N=114 | Screening score >2 on the CAGE alcohol screening questionnaire; pregnant or currently nursing; planning to disenroll from the GHC insurance plan in the next 12 months; currently seeing a psychiatrist; non English speaking; recently using lithium or antipsychotic medication
Katon, 1996 ^35^ | English speaking, adult age 18 to 80 years old, beginning antidepressants. Average age 46, 74% female, 87% white | Current alcohol abuse; current psychotic symptoms or serious suicidal ideation or plan; dementia; pregnancy; terminal illness; limited command of English; plan to withdraw from GHC insurance plan within the next 12 months
Katon, 2001 ^36,^ ^37^ | English speaking, current adult patients beginning antidepressants. Patients at high risk of relapse, recovered from depression 6 to 8 weeks after initiation of pharmacotherapy by their PCP. Average age 46, 73% female, 90% white. Control N=192, Intervention N=194 | N/A
Capoccia 2004 ^38,^ ^39^ | English speaking current adult patients beginning antidepressants. Average age 39, 57% female, 22% non-white. Control N=33, Intervention N=41 | Age <18 years; terminal medical illness; cognitive impairment; psychosis; current alcohol or substance abuse; suicide attempts or current suicide plan; pregnant or nursing; limited command of English; not intending to use the FMC as a source of care for the next 12 months
Tutty, 2000 ^40^ | Adult patients beginning antidepressants. Average age 47, 69% female. Control N=94, Intervention N=28 | Bipolar disorder, schizophrenia, or schizoaffective disorder during past 2 years; active alcohol or other substance abuse during the previous 90 days; or visit to a psychiatrist within the previous 90 days.
Hunkeler 2000 ^41^ | English speaking adults with SSRI prescription for depression. About 70% female, 37% non-white. Control N=123 Intervention N=179 | Previous antidepressant drug prescription within the past 6 months; inadequate command of the English language; reported current problems with substance abuse; current suicide risk; reported thoughts of violence.
QuEST ^39,^ ^42,^ ^43^ | English reading current adult patients with depression. Average age 43, 84% female, 16% non-white. Control N=240, Intervention N=239 | Bereavement, mania, alcohol dependence, pregnancy or the postpartum period, life threatening physical illness; no intent to use the clinic as their usual source of care during the year after the index visit; no telephone access; patients who were illiterate in English cognitively impaired.
Simon, 2000 ^44^ | Current adult patients newly prescribed antidepressants. Average age 46 years, 72% female. Control N=196 | Nondepression indication for prescription; bipolar disorder or psychotic disorder in the previous two years; alcohol or other substance misuse in the previous 90 days; or had visited a psychiatrist in the previous 90 days.
Hilty, 2007 ^45^ | English speaking current adult patients with depression willing to take antidepressants | Without a primary diagnosis of major depression; suicidal intention or plans; dementia, pregnancy, terminal illness, and plans to move in the next 12 months; all other psychiatric and medical disorders.
Katzelnick, 2000 ^46^ | Current adult patients above 85^th^ percentile in utilization for previous 2 years | Recent treatment for alcohol or other substance abuse; past treatment for schizophrenia or bipolar disorder; life-threatening medical disorders; active treatment for depression.
Anxiety Disorders
Roy-Byrne 2001 ^47^ | English speaking adult patients with at least 1 panic attack in last month. Average age 41, 57% female, 67% white | Currently receiving psychiatric treatment and receiving or applying for disability benefits
CCAP ^48,^ ^49^ | English speaking adult patients between 18 and 70 years of age with at least 1 panic attack within last week. Average age 41, 67% female, 66% white, Control N=113, Intervention N=119 | Suicidal ideation, terminal medical illness, psychosis, current substance abuse, dementia, pregnancy; already on psychiatrist or CBT.
CALM ^50^ | English speaking adult current patients with GAD, PTSD, PD and SAD | Serious alcohol or drug use; unstable medical conditions, marked cognitive impairment, active suicidal intent/plan, psychosis or bipolar I disorder; ongoing medication management or CBT; without routine access to a telephone or who could not speak English or Spanish
Rollman, 2005 ^51,^ ^52^ | English speaking, adult current patients with anxiety disorders. Average age 44 years, 81% female, 95% white. Control N=75, Intervention N=116 | Receiving treatment from a mental health professional; bipolar disorder; leave the study practice within the following year.
Price, 2000 ^53^ | English speaking, adult current patients with GAD. Mean age 49 years, 80% female, 86% white. Control N=111, Intervention N=113 | Current alcohol and substance abuse, planned to disenroll from Kaiser Permanente within 12 months from entrance into the study, had difficulty speaking English; psychosis or dementia; terminal illness
Somatizing Disorders
Katon, 1992 ^54^ | Top 10% adult ambulatory care utilizes of appropriate age group with psychiatric distress, SCL >13. Average age 47, 61% female | Pregnant; not known to the physician; dementia or psychotic illness; terminally ill or too ill to participate; changing physicians; terminating GHC enrollment within the next year
Escobar, 2007 ^55^ | Adults with undiagnosed somatic symptoms. 88% female, 68% Hispanic. Mean age 40. Control N=85, Intervention N=87 | insufficient somatization; scheduling difficulties; psychiatric exclusions; concurrent treatment; medical exclusions; concurrent legal issues.
Other
Epstein, 2007 ^56^ | 1^st^ through 5^th^ grade children with ADHD | Not reported
PRISM-E (for at-risk alcohol use) ^4,^ ^5,^ ^57^ | Elderly primary care patients. 92% male, 70% white, mean age 72, Intervention N=280, Referral N=280 | Psychosis, mania, hypomania, severe cognitive impairment
Backward Integration
Weisner, 2001 ^58^ | Adult patients admitted to a chemical dependency program. Mean age 37, 55% male, 74% white. Control N=307, Intervention N=285 | N/A
Druss, 2001 ^59^ | VA mental health patients without a current primary care provider. Mean age 45, 99% male, 70% white, Control N=61, Intervention N=59 | With current PCP or an urgent or multiple serious chronic problems
Willenbring, 1999 ^60^ | VA patients with current alcohol abuse behavior and alcohol-related medical illness. Mean age 55.1, Control N=53, Intervention N=48 | Terminal illness with a life expectancy of less than 12 months from a nonalcohol-related illness; severe dementia; major psychiatric disorder other than depression; current polysubstance abuse or drug of choice other than alcohol; civil commitment to treatment or a pending commitment action.

## References for Appendix D

1 Fortney JC, Pyne JM, Edlund MJ, et al. A randomized trial of telemedicine-based collaborative care for depression. Journal of General Internal Medicine. Aug. 2007;22(8):1086-93. [pmid: 17492326].
2 Fortney JC, Pyne JM, Edlund MJ, et al. Design and implementation of the telemedicine-enhanced antidepressant management study. General Hospital Psychiatry. Jan–Feb. 2006;28(1):18-26. [pmid: 16377361].
3 Krahn DD, Bartels SJ, Coakley E, et al. PRISM-E: comparison of integrated care and enhanced specialty referral models in depression outcomes. Psychiatric Services. Jul. 2006;57(7):946-53. [pmid: 16816278].
4 Bartels SJ, Coakley EH, Zubritsky C, et al. Improving access to geriatric mental health services: a randomized trial comparing treatment engagement with integrated versus enhanced referral care for depression, anxiety, and at-risk alcohol use.[see comment]. American Journal of Psychiatry. Aug. 2004;161(8):1455-62. [pmid: 15285973].
5 Levkoff SE, Chen H, Coakley E, et al. Design and sample characteristics of the PRISM-E multisite randomized trial to improve behavioral health care for the elderly. Journal of Aging & Health. Feb. 2004;16(1):3-27. [pmid: 14979308].
6 Geron SM, Keefe B. Moving evidence-based interventions to populations: a case study using social workers in primary care. Home Health Care Services Quarterly. 2006;25(12):95-113. [pmid: 16803740].
7 Grypma L, Haverkamp R, Little S, et al. Taking an evidence-based model of depression care from research to practice: making lemonade out of depression.[see comment]. General Hospital Psychiatry. Mar–Apr. 2006;28(2):101-7. [pmid: 16516059].
8 Hunkeler EM, Katon W, Tang L, et al. Long term outcomes from the IMPACT randomised trial for depressed elderly patients in primary care.[see comment]. BMJ. Feb 4. 2006;332(7536):259-63. [pmid: 16428253].
9 Callahan CM, Kroenke K, Counsell SR, et al. Treatment of depression improves physical functioning in older adults.[see comment]. Journal of the American Geriatrics Society. Mar. 2005;53(3):367-73. [pmid: 15743276].
10 Unutzer J, Tang L, Oishi S, et al. Reducing suicidal ideation in depressed older primary care patients.[see comment]. Journal of the American Geriatrics Society. Oct. 2006;54(10):1550-6. [pmid: 17038073].
11 Unutzer J, Katon W, Callahan CM, et al. Collaborative care management of late-life depression in the primary care setting: a randomized controlled trial.[see comment]. JAMA. Dec 11. 2002;288(22):2836-45. [pmid: 12472325].
12 Unutzer J, Katon W, Williams JW Jr, et al. Improving primary care for depression in late life: the design of a multicenter randomized trial. Medical Care. Aug. 2001;39(8):785-99. [pmid: 11468498].
13 Clarke G, Debar L, Lynch F, et al. A randomized effectiveness trial of brief cognitive-behavioral therapy for depressed adolescents receiving antidepressant medication. Journal of the American Academy of Child & Adolescent Psychiatry. Sep. 2005;44(9):888-98. [pmid: 16113617].
14 Alexopoulos GS, Katz IR, Bruce ML, et al. Remission in depressed geriatric primary care patients: a report from the PROSPECT study. American Journal of Psychiatry. Apr. 2005;162(4):718-24. [pmid: 15800144].
15 Bruce M, Ten Have T, Reynolds Cr, et al. Reducing suicidal ideation and depressive symptoms in depressed older primary care patients: a randomized controlled trial. JAMA. Mar 3. 2004;291(9):1081-91. [pmid: 14996777].
16 Bruce ML, Pearson JL. Designing an intervention to prevent suicide: PROSPECT (Prevention of Suicide in Primary Care Elderly: Collaborative Trial). Dialogues in Clinical Neuroscience. 1999;1(2):100-12. [pmid: 22033641].
17 Katon WJ, Von Korff M, Lin EH, et al. The Pathways Study: a randomized trial of collaborative care in patients with diabetes and depression.[see comment]. Archives of General Psychiatry. Oct. 2004;61(10):1042-9. [pmid: 15466678].
18 Katon W, Von Korff M, Lin E, et al. Improving primary care treatment of depression among patients with diabetes mellitus: the design of the pathways study. General Hospital Psychiatry. May–Jun. 2003;25(3):158-68. [pmid: 12748028].
19 Dietrich AJ, Oxman TE, Williams JW Jr, et al. Re-engineering systems for the treatment of depression in primary care: cluster randomised controlled trial.[see comment]. BMJ. Sep 11. 2004;329(7466):602. [pmid: 15345600].
20 Oxman T, Dietrich A, Williams JJ, et al. A three-component model for reengineering systems for the treatment of depression in primary care. Psychosomatics. Nov–Dec. 2002;43(6):441-50. [pmid: 12444226].
21 Simon GE, Ludman EJ, Tutty S, et al. Telephone psychotherapy and telephone care management for primary care patients starting antidepressant treatment: a randomized controlled trial.[see comment]. JAMA. Aug 25. 2004;292(8):935-42. [pmid: 15328325].
22 Adler DA, Bungay KM, Wilson IB, et al. The impact of a pharmacist intervention on 6-month outcomes in depressed primary care patients. General Hospital Psychiatry. May–Jun. 2004;26(3):199-209. [pmid: 15121348].
23 Bungay KM, Adler DA, Rogers WH, et al. Description of a clinical pharmacist intervention administered to primary care patients with depression. General Hospital Psychiatry. May–Jun. 2004;26(3):210-8. [pmid: 15121349].
24 Finley PR, Rens HR, Pont JT, et al. Impact of a collaborative care model on depression in a primary care setting: a randomized controlled trial. Pharmacotherapy. Sep. 2003;23(9):1175-85. [pmid: 14524649].
25 Swindle RW, Rao JK, Helmy A, et al. Integrating clinical nurse specialists into the treatment of primary care patients with depression. International Journal of Psychiatry in Medicine. 2003;33(1):17-37. [pmid: 12906341].
26 Jaycox LH, Miranda J, Meredith LS, et al. Impact of a primary care quality improvement intervention on use of psychotherapy for depression. Mental Health Services Research. Jun. 2003;5(2):109-20. [pmid: 12801074].
27 Sherbourne CD, Wells KB, Duan N, et al. Long-term effectiveness of disseminating quality improvement for depression in primary care. Archives of General Psychiatry. Jul. 2001;58(7):696-703. [pmid: 11448378].
28 Schoenbaum M, Unutzer J, McCaffrey D, et al. The effects of primary care depression treatment on patients' clinical status and employment. Health Services Research. Oct. 2002;37(5):1145-58. [pmid: 12479490].
29 Wells K. The design of Partners in Care: evaluating the cost-effectiveness of improving care for depression in primary care. Social Psychiatry & Psychiatric Epidemiology. Jan. 1999;34(1):20-9. [pmid: 10073117].
30 Wells K, Sherbourne C, Schoenbaum M, et al. Impact of disseminating quality improvement programs for depression in managed primary care: a randomized controlled trial. JAMA. Jan 12. 2000;283(2):212-20. [pmid: 10634337].
31 Datto CJ, Thompson R, Horowitz D, et al. The pilot study of a telephone disease management program for depression. General Hospital Psychiatry. May–Jun. 2003;25(3):169-77. [pmid: 12748029].
32 Hedrick SC, Chaney EF, Felker B, et al. Effectiveness of collaborative care depression treatment in Veterans' Affairs primary care.[see comment]. Journal of General Internal Medicine. Jan. 2003;18(1):9-16. [pmid: 12534758].
33 Katon W, Von Korff M, Lin E, et al. Collaborative management to achieve depression treatment guidelines. Journal of Clinical Psychiatry. 1997;58(Suppl 1):20-3. [pmid: 9054905].
34 Katon W, Von Korff M, Lin E, et al. Stepped collaborative care for primary care patients with persistent symptoms of depression: a randomized trial. Archives of General Psychiatry. Dec. 1999;56(12):1109-15. [pmid: 10591288].
35 Katon W, Robinson P, Von Korff M, et al. A multifaceted intervention to improve treatment of depression in primary care. Archives of General Psychiatry. Oct. 1996;53(10):924-32. [pmid: 8857869].
36 Katon W, Rutter C, Ludman EJ, et al. A randomized trial of relapse prevention of depression in primary care. Archives of General Psychiatry. Mar. 2001;58(3):241-7. [pmid: 11231831].
37 Ludman E, Von Korff M, Katon W, et al. The design, implementation, and acceptance of a primary care-based intervention to prevent depression relapse. International Journal of Psychiatry in Medicine. 2000;30(3):229-45. [pmid: 11209991].
38 Boudreau DM, Capoccia KL, Sullivan SD, et al. Collaborative care model to improve outcomes in major depression. Annals of Pharmacotherapy. Apr. 2002;36(4):585-91. [pmid: 11918503].
39 Capoccia KL, Boudreau DM, Blough DK, et al. Randomized trial of pharmacist interventions to improve depression care and outcomes in primary care. American Journal of Health-System Pharmacy. Feb 15. 2004;61(4):364-72. [pmid: 15011764].
40 Tutty S, Simon G, Ludman E. Telephone counseling as an adjunct to antidepressant treatment in the primary care system. A pilot study.[see comment]. Effective Clinical Practice. Jul–Aug. 2000;3(4):170-8. [pmid: 11183432].
41 Hunkeler EM, Meresman JF, Hargreaves WA, et al. Efficacy of nurse telehealth care and peer support in augmenting treatment of depression in primary care.[see comment][comment]. Archives of Family Medicine. Aug. 2000;9(8):700-8. [pmid: 10927707].
42 Rost K, Nutting PA, Smith J, et al. Designing and implementing a primary care intervention trial to improve the quality and outcome of care for major depression. General Hospital Psychiatry. Mar–Apr. 2000;22(2):66-77. [pmid: 10822094].
43 Rost K, Nutting P, Smith JL, et al. Managing depression as a chronic disease: a randomised trial of ongoing treatment in primary care. BMJ. Oct 26. 2002;325(7370):934-7. [pmid: 12399343].
44 Simon G, VonKorff M, Rutter C, et al. Randomised trial of monitoring, feedback, and management of care by telephone to improve treatment of depression in primary care.[see comment]. BMJ. Feb 26. 2000;320(7234):550-4. [pmid: 10688563].
45 Hilty DM, Marks S, Wegeland J, et al. A randomized, controlled trial of disease management modules, including telepsychiatric care, for depression in rural primary care. Psychiatry. Feb. 2007;4(2):58-65. [pmid: 20805900].
46 Katzelnick D, Simon G, Pearson S, et al. Randomized trial of a depression management program in high utilizers of medical care.[see comment]. Archives of Family Medicine. Apr. 2000;9(4):345-51. [pmid: 10776363].
47 Roy-Byrne PP, Katon W, Cowley DS, et al. A randomized effectiveness trial of collaborative care for patients with panic disorder in primary care.[see comment]. Archives of General Psychiatry. Sep. 2001;58(9):869-76. [pmid: 11545671].
48 Roy-Byrne P, Stein MB, Russo J, et al. Medical illness and response to treatment in primary care panic disorder. General Hospital Psychiatry. Jul–Aug. 2005;27(4):237-43. [pmid: 15993254].
49 Roy-Byrne PP, Craske MG, Stein MB, et al. A randomized effectiveness trial of cognitive-behavioral therapy and medication for primary care panic disorder.[see comment]. Archives of General Psychiatry. Mar. 2005;62(3):290-8. [pmid: 15753242].
50 Sullivan G, Craske MG, Sherbourne C, et al. Design of the Coordinated Anxiety Learning and Management study: Innovations in collaborative care for anxiety disorders. General Hospital Psychiatry. Sep–Oct. 2007;29(5):379-87. [pmid: 17888803].
51 Rollman BL, Belnap BH, Mazumdar S, et al. A randomized trial to improve the quality of treatment for panic and generalized anxiety disorders in primary care. Archives of General Psychiatry. Dec. 2005;62(12):1332-41. [pmid: 16330721].
52 Rollman BL, Herbeck Belnap B, Reynolds CF, et al. A contemporary protocol to assist primary care physicians in the treatment of panic and generalized anxiety disorders. General Hospital Psychiatry. Mar–Apr. 2003;25(2):74-82. [pmid: 12676419].
53 Price D, Beck A, Nimmer C, et al. The treatment of anxiety disorders in a primary care. HMO setting Psychiatric Quarterly. 2000;71(1):31-45. [pmid: 10736815].
54 Katon W, Von Korff M, Lin E, et al. A randomized trial of psychiatric consultation with distressed high utilizers. General Hospital Psychiatry. Mar. 1992;14(2):86-98. [pmid: 1592254].
55 Escobar JI, Gara MA, Diaz-Martinez AM, et al. Effectiveness of a time-limited cognitive behavior therapy type intervention among primary care patients with medically unexplained symptoms. Annals of Family Medicine. Jul–Aug. 2007;5(4):328-35. [pmid: 17664499].
56 Epstein JN, Rabiner D, Johnson DE, et al. Improving attention-deficit/hyperactivity disorder treatment outcomes through use of a collaborative consultation treatment service by community-based pediatricians: a cluster randomized trial. Archives of Pediatrics & Adolescent Medicine. Sep. 2007;161(9):835-40. [pmid: 17768282].
57 Oslin DW, Grantham S, Coakley E, et al. PRISM-E: comparison of integrated care and enhanced specialty referral in managing at-risk alcohol use.[erratum appears in Psychiatr Serv 2006 Oct;57(10):1492 Note: Olsen, Ed [added]; Kirchner, JoAnn E [added]; Levkoff, Sue [added]]. Psychiatric Services. Jul. 2006;57(7):954-8. [pmid: 16816279].
58 Weisner C, Mertens J, Parthasarathy S, et al. Integrating primary medical care with addiction treatment: a randomized controlled trial.[see comment]. JAMA. Oct 10. 2001;286(14):1715-23. [pmid: 11594896].
59 Druss BG, Rohrbaugh RM, Levinson CM, et al. Integrated medical care for patients with serious psychiatric illness: a randomized trial.[see comment]. Archives of General Psychiatry. Sep. 2001;58(9):861-8. [pmid: 11545670].
60 Willenbring M, Olson D. A randomized trial of integrated outpatient treatment for medically ill alcoholic men. Archives of Internal Medicine. Sep 13. 1999;159(16):1946-52. [pmid: 10493326].