# Appendix C: Data Abstraction Form

To see the Data Abstraction Form, please select the link below. This link will take you to a PDF version of the Data Abstraction Form.

Data Abstraction Form