# Appendix A: Technical Expert Panel Members and Affiliation

TEP Member | Affiliation
Mady Chalk, PhD | Center for Performance-based Policy Treatment Research Institute Philadelphia, Pennsylvania
Benjamin Druss, MD, MPH | Department of Health Policy and Management Rollins School of Public Health Atlanta, Georgia
Michael Fitzpatrick, MSW | National Alliance on Mental Illness Arlington, Virginia
Wayne Katon, MD, BS | Department of Psychiatry and Behavioral Sciences University of Washington Seattle, Washington
David Mechanic, PhD | Institute for Health, Health Care Policy, and Aging Research, Rutgers New Brunswick, New Jersey