# List of Acronyms/Abbreviations

ADHD | Attention deficit and hyperactivity disorder
AHCPR | Agency for Health Care Policy and Research
AHRQ | Agency for Healthcare Research and Quality
BHCAG | Buyers Health Care Action Group
BHC | Behavioral health consultant
BHS | Behavioral Health Services
BMS | Behavioral medical specialist
BTE | Bridges to excellence
CBT | Cognitive behavioral therapy
CCM | Chronic care model
CE | Cost effectiveness
CHS | Cherokee Health System
CI | Confidence interval
CMS | Center for Medicare and Medicaid Services
CNS | Clinical nurse specialist
CPT | Current procedural terminology
CQI | Continuous quality improvement
DHHS | Department of Health and Human Services
DM | Disease management
EBCI | Eastern Band of Cherokee Indians
EHR | Electronic health record
GEM | Geriatric evaluation and management
GHC | Group Health Cooperative
HCO | Health care organizations
HEDIS | Healthcare effectiveness data and information set
HIPAA | Health Insurance Portability and Accountability Act
HMO | Health maintenance organization
HRA | Health risk assessment
HRSA | Health Resources and Services Administration
ICSI | Institute for Clinical Systems Improvement
IHS | Indian Health Service
IMBH | Integrated Medical and Behavioral Health
IOM | Institute of Medicine
IPA | Independent practice association
IPT | Interpersonal therapy
IT | Information technology
MBHO | Managed Behavioral Health Organization
MCO | Managed care organization
MeSH | Medical subject heading
MHI | Mental health integration
NAMI | National Alliance on Mental Illness
NBCH | National Business Coalition for Health
NCQA | National Committee for Quality Assurance
OR | Odds ratio
PBM | Pharmacy benefits manager
PCP | Primary care provider
PMPM | Per member per month
PPO | Preferred provider organization
PST | Problem solving therapy
PTSD | Post-traumatic stress disorder
QALY | Quality adjusted life year
QI | Quality indicators
QUERI | Quality enhancement research initiative
RCT | Randomized controlled trials
RETIDES | Regional expansion of translating initiatives in depression into effective solutions
ROI | Return on investment
SAMHSA | Substance Abuse and Mental Health Services Administration
SCID | Structured Clinical Interview for DSM-IV
SPMI | Severe and persistent mental illness
TCM | Three component model
TEP | Technical expert panel
TIDES | Translating initiatives in depression into effective solutions
UCSF | University of California San Francisco
UMHS | University of Michigan Health System
VA | Veterans Administration
VISN | Veterans integrated service network
WCHO | Washtenaw County Health Organization