# References and Included Studies

(Note that there is a separate set of references at the end of the evidence table in Appendix E and at the end of the patient inclusion and exclusion criteria in Appendix F. The reference numbers there are different from those in the text of the report)

1 New Freedom Commission on Mental Health. Achieving the Promise: Transforming Mental Health Care in America. Final Report. Rockville, MD: DHHS; retrieved May 27, 2008 2003.
2 Hunkeler EM, Katon W, Tang L, et al. Long term outcomes from the IMPACT randomised trial for depressed elderly patients in primary care.[see comment]. BMJ. Feb 4. 2006;332(7536):259-63. [pmid: 16428253].
3 Katon W, Russo J, Von Korff M, et al. Long-term effects of a collaborative care intervention in persistently depressed primary care patients.[see comment]. Journal of General Internal Medicine. Oct. 2002;17(10):741-8. [pmid: 12390549].
4 Lin EH, Simon GE, Katon WJ, et al. Can enhanced acute-phase treatment of depression improve long-term outcomes? A report of randomized trials in primary care. American Journal of Psychiatry. Apr. 1999;156(4):643-5. [pmid: 10200750].
5 Rost K, Nutting P, Smith JL, et al. Managing depression as a chronic disease: a randomised trial of ongoing treatment in primary care. BMJ. Oct 26. 2002;325(7370):934-7. [pmid: 12399343].
6 Wells K, Sherbourne C, Schoenbaum M, et al. Five-year impact of quality improvement for depression: results of a group-level randomized controlled trial. Arch Gen Psychiatry. 2004;61(4):378-86. [pmid: 15066896].
7 Sullivan G, Craske MG, Sherbourne C, et al. Design of the Coordinated Anxiety Learning and Management study: Innovations in collaborative care for anxiety disorders. General Hospital Psychiatry. Sep–Oct. 2007;29(5):379-87. [pmid: 17888803].
8 Thielke SM, Fan MY, Sullivan M, et al. Pain limits the effectiveness of collaborative care for depression. American Journal of Geriatric Psychiatry. Aug. 2007;15(8):699-707. [pmid: 17670998].
9 Roy-Byrne P, Stein MB, Russo J, et al. Medical illness and response to treatment in primary care panic disorder. General Hospital Psychiatry. Jul–Aug. 2005;27(4):237-43. [pmid: 15993254].
10 Harpole LH, Williams JW Jr, Olsen MK, et al. Improving depression outcomes in older adults with comorbid medical illness.[see comment]. General Hospital Psychiatry. Jan–Feb. 2005;27(1):4-12. [pmid: 15694213].
11 Bogner H, Cary M, Bruce M, et al. The role of medical comorbidity in outcome of major depression in primary care: the PROSPECT study. American Journal of Geriatric Psychiatry. Oct. 2005;13(10):861-8. [pmid: 16223964].
12 Kinder LS, Katon WJ, Ludman E, et al. Improving depression care in patients with diabetes and multiple complications.[see comment]. Journal of General Internal Medicine. Oct. 2006;21(10):1036-41. [pmid: 16836628].
13 Sherbourne CD, Weiss R, Duan N, et al. Do the effects of quality improvement for depression care differ for men and women? Results of a group-level randomized controlled trial. Medical Care. Dec. 2004;42(12):1186-93. [pmid: 15550798].
14 Kautz C, Mauch D, Smith SA. Reimbursement of Mental Health Services in Primary Care Settings. Rockville, MD: Center for Mental Health Services, Substance Abuse and Mental Health Services Administration; 2007. HHS Pub. No. SMA-08-4324.
15 Druss BG, von Esenwein SA. Improving general medical care for persons with mental and addictive disorders: systematic review. General Hospital Psychiatry. Mar–Apr. 2006;28(2):145-53. [pmid: 16516065].
16 Druss BG, Rohrbaugh RM, Levinson CM, et al. Integrated medical care for patients with serious psychiatric illness: a randomized trial.[see comment]. Archives of General Psychiatry. Sep. 2001;58(9):861-8. [pmid: 11545670].
17 Weisner C, Mertens J, Parthasarathy S, et al. Integrating primary medical care with addiction treatment: a randomized controlled trial.[see comment]. JAMA. Oct 10. 2001;286(14):1715-23. [pmid: 11594896].
18 Parthasarathy S, Mertens J, Moore C, et al. Utilization and cost impact of integrating substance abuse treatment and primary care. Medical Care. Mar. 2003;41(3):357-67. [pmid: 12618639].
19 Groopman JE. How doctors think. Boston: Houghton Mifflin Co; 2007.
20 Beach MC, Meredith LS, Halpern J, et al. Physician conceptions of responsibility to individual patients and distributive justice in health care. Annals of Family Medicine. Jan–Feb. 2005;3(1):53-9. [pmid: 15671191].
21 Rothman AA, Wagner EH. Chronic illness management: what is the role of primary care?.[see comment]. Annals of Internal Medicine. Feb 4. 2003;138(3):256-61. [pmid: 12558376].
22 Wang PS, Lane M, Olfson M, et al. Twelve-month use of mental health services in the United States: results from the National Comorbidity Survey Replication.[see comment]. Archives of General Psychiatry. Jun. 2005;62(6):629-40. [pmid: 15939840].
23 Blount A. Integrated Primary Care: Organizing the Evidence. Families, Systems, & Health. Sum. 2003;21(2):121-33.
24 Druss BG. Improving medical care for persons with serious mental illness: challenges and solutions. Journal of Clinical Psychiatry. 2007;68(Suppl 4):40-4. [pmid: 17539699].
25 McAlpine DD, Mechanic D. Utilization of specialty mental health care among persons with severe mental illness: the roles of demographics, need, insurance, and risk. Health Services Research. Apr. 2000;35(1 Pt 2):277-92. [pmid: 10778815].
26 National Center for Health Statistics. With Chartbook on Trends in the Health of Americans. Hyattsville, MD 2007.
27 Stang PE, Brandenburg NA, Lane MC, et al. Mental and physical comorbid conditions and days in role among persons with arthritis. Psychosomatic Medicine. Jan–Feb. 2006;68(1):152-8. [pmid: 16449426].
28 Lett HS, Blumenthal JA, Babyak MA, et al. Depression as a risk factor for coronary artery disease: evidence, mechanisms, and treatment. Psychosomatic Medicine. May–Jun. 2004;66(3):305-15. [pmid: 15184688].
29 Astle F. Diabetes and depression: a review of the literature. Nursing Clinics of North America. Mar. 2007;42(1):67-78. [pmid: 17270591].
30 Merikangas KR, Ames M, Cui L, et al. The impact of comorbidity of mental and physical conditions on role disability in the US adult household population. Archives of General Psychiatry. Oct. 2007;64(10):1180-8. [pmid: 17909130].
31 Kathol R, Saravay SM, Lobo A, et al. Epidemiologic trends and costs of fragmentation. Medical Clinics of North America. Jul. 2006;90(4):549-72. [pmid: 16843762].
32 Kessler RC, Ormel J, Demler O, et al. Comorbid mental disorders account for the role impairment of commonly occurring chronic physical disorders: results from the National Comorbidity Survey. Journal of Occupational & Environmental Medicine. Dec. 2003;45(12):1257-66. [pmid: 14665811].
33 Schulberg HC, Katon W, Simon GE, et al. Treating major depression in primary care practice: an update of the Agency for Health Care Policy and Research Practice Guidelines. Archives of General Psychiatry. Dec. 1998;55(12):1121-7. [pmid: 9862556].
34 Schweizer E, Rickels K. Strategies for treatment of generalized anxiety in the primary care setting.[see comment]. Journal of Clinical Psychiatry. 1997;58(Suppl 3):27-31. discussion 2–3. [pmid: 9133490].
35 Stein MB, Sherbourne CD, Craske MG, et al. Quality of care for primary care patients with anxiety disorders. American Journal of Psychiatry. Dec. 2004;161(12):2230-7. [pmid: 15569894].
36 Young AS, Klap R, Sherbourne CD, et al. The quality of care for depressive and anxiety disorders in the United States. Archives of General Psychiatry. Jan. 2001;58(1):55-61. [pmid: 11146758].
37 Kelly DL, Boggs DL, Conley RR. Reaching for wellness in schizophrenia. Psychiatric Clinics of North America. Sep. 2007;30(3):453-79. [pmid: 17720032].
38 Nasrallah HA, Meyer JM, Goff DC, et al. Low rates of treatment for hypertension, dyslipidemia and diabetes in schizophrenia: data from the CATIE schizophrenia trial sample at baseline. Schizophrenia Research. Sep. 2006;86(13):15-22. [pmid: 16884895].
39 Salsberry PJ, Chipps E, Kennedy C. Use of general medical services among Medicaid patients with severe and persistent mental illness. Psychiatric Services. Apr. 2005;56(4):458-62. [pmid: 15812097].
40 Mauer B, Druss B. Mind and Body Reunited: Improving Care at the Behavioral and Primary Healthcare Interface: American College of Mental Health Administration; National Council for Community Behavioral Healthcare; Carter Center Mental Health Program; March 2007.
41 Mauer B. Morbidity and Mortality in People with Serious Mental Illness. Alexandria, VA: National Association of State Mental Health Program Directors; Medical Directors Council; October 2006.
42 Samet JH, Friedmann P, Saitz R. Benefits of linking primary medical care and substance abuse services: patient, provider, and societal perspectives. Archives of Internal Medicine. Jan 8. 2001;161(1):85-91. [pmid: 11146702].
43 De Alba I, Samet JH, Saitz R. Burden of medical illness in drug- and alcohol-dependent persons without primary care. American Journal on Addictions. Jan–Feb. 2004;13(1):33-45. [pmid: 14766436].
44 Lieber CS. Hepatic and other medical disorders of alcoholism: from pathogenesis to treatment. Journal of Studies on Alcohol. Jan. 1998;59(1):9-25. [pmid: 9498311].
45 Saitz R, Horton NJ, Larson MJ, et al. Primary medical care and reductions in addiction severity: a prospective cohort study. Addiction. Jan. 2005;100(1):70-8. [pmid: 15598194].
46 Wagner EH, Austin BT, Von Korff M. Organizing care for patients with chronic illness. The Milbank Quarterly. 1996;74(4):511-43. [pmid: 8941260].
47 DMAA. Available at: http://www.dmaa.org/definition.asp. Accessed March 13.
48 Von Korff M, Gruman J, Schaefer J, et al. Collaborative management of chronic illness. Annals of Internal Medicine. Dec 15. 1997;127(12):1097-102. [pmid: 9412313].
49 Sobel DS. Rethinking medicine: improving health outcomes with cost-effective psychosocial interventions. Psychosomatic Medicine. May–Jun. 1995;57(3):234-44. [pmid: 7652124].
50 Seaburn DB, Lorenz AD, Gunn J, William B., et al. Models of Collaboration. A Guide for Mental Health Professionals Working with Health Care Practitioners. New York, NY: Basic Books; 1996.
51 Institute of Medicine. Crossing the Quality Chasm: A New Health System for the 21st Century. Washington, DC: National Academy Press; 2001.
52 Wulsin LR, Sollner W, Pincus HA. Models of integrated care. Medical Clinics of North America. Jul. 2006;90(4):647-77. [pmid: 16843767].
53 Hogg Foundation for Mental Health. The University of Texas at Austin. Available at: http://www.hogg.utexas.edu/programs_ihc.html. Accessed May 27.
54 VA Healthcare Network Upstate New York. Integrated Primary Care Behavioral Health Services Operations Manual: VISN #2; 2005.
55 Institute of Medicine. Improving the Quality of Health Care for Mental and Substance-Use Conditions. Washington, DC: The National Academies Press; 2006.
56 Doherty WJ, McDaniel SH, Baird MA. Five levels of primary care/behavioral healthcare collaboration. Behavioral Healthcare Tomorrow. Oct. 1996;5(5):25-7. [pmid: 10161572].
57 Simon GE, VonKorff M. Recognition, management, and outcomes of depression in primary care.[see comment]. Archives of Family Medicine. Feb. 1995;4(2):99-105. [pmid: 7842160].
58 Ormel J, Koeter MW, Van den Brink W, et al. Recognition, management, and course of anxiety and depression in general practice. Archives of General Psychiatry. Aug. 1991;48(8):700-6. [pmid: 1883252].
59 Shortell SM, Gillies RR, Anderson DA, et al. Remaking health care in America: building organized delivery systems. 2nd ed. San Francisco: Jossey-Bass Publishers; 2000.
60 Bower P, Gilbody S, Richards D, et al. Collaborative care for depression in primary care. Making sense of a complex intervention: systematic review and meta-regression. British Journal of Psychiatry. Dec. 2006;189:484-93. [pmid: 17139031].
61 Horvitz-Lennon M, Kilbourne AM, Pincus HA. From silos to bridges: meeting the general health care needs of adults with severe mental illnesses. Health Affairs. May–Jun. 2006;25(3):659-69. [pmid: 16684729].
62 Pincus HA, Pechura C, Keyser D, et al. Depression in primary care: learning lessons in a national quality improvement program. Administration & Policy in Mental Health. Jan. 2006;33(1):2-15. [pmid: 16215667].
63 Druss BG, Newcomer JW. Challenges and solutions to integrating mental and physical health care. Journal of Clinical Psychiatry. Apr. 2007;68(4):e09. [pmid: 17474799].
64 Gilbody S, Bower P, Fletcher J, et al. Collaborative care for depression: a cumulative meta-analysis and review of longer-term outcomes.[see comment]. Archives of Internal Medicine. Nov 27. 2006;166(21):2314-21. [pmid: 17130383].
65 Robinson PJ, Reiter Jt. Behavioral Consultation and Primary Care. A Guide to Integrating Services. New York, NY: Springer Science; 2007.
66 Byrd MR, O'Donohue WT, Cummings NA. The case for integrated care: Coordinating behavioral health care with primary care medicine. In: O'Donohue WT, Byrd MR, Cummings NA, et al., eds. Behavioral Integrative Care. Treatments that work in the primary care setting. New York, NY: Brunner-Routledge; 2005.
67 Smith SM, Allwright S, O'Dowd T. Effectiveness of shared care across the interface between primary and specialty care in chronic disease management Cochrane Database of Systematic Reviews 2007; (3):CD004910.
68 American Psychological Association, Presidential Task Force on Integrated Health Care for and Aging Population. Blueprint for change: Achieving integrated health care for an aging population. Washington, DC: American Psychological Association; 2008.
69 Katon W, Von Korff M, Lin E, et al. Improving primary care treatment of depression among patients with diabetes mellitus: the design of the pathways study. General Hospital Psychiatry. May–Jun. 2003;25(3):158-68. [pmid: 12748028].
70 Gagne M. What is collaborative mental health care? An introduction to the collaborative mental health care framework. Canadian Collaborative Mental Health Initiative. Available at: http://www.ccmhi.co/en/products/series_of_papers.html. Accessed September 12, 2008.
71 Badamgarav E, Weingarten SR, Henning JM, et al. Effectiveness of disease management programs in depression: a systematic review.[see comment]. American Journal of Psychiatry. Dec. 2003;160(12):2080-90. [pmid: 14638573].
72 Craven MA, Bland R. Better practices in collaborative mental health care: an analysis of the evidence base. Canadian Journal of Psychiatry - Revue Canadienne de Psychiatrie. May. 2006;51(6 Suppl 1):7S-72S. [pmid: 16786824].
73 Gensichen J, Beyer M, Muth C, et al. Case management to improve major depression in primary health care: a systematic review.[see comment]. Psychological Medicine. Jan. 2006;36(1):7-14. [pmid: 16356292].
74 Gilbody S, Whitty P, Grimshaw J, et al. Educational and organizational interventions to improve the management of depression in primary care: a systematic review.[see comment]. JAMA. Jun 18. 2003;289(23):3145-51. [pmid: 12813120].
75 Gilbody S, Bower P, Whitty P. Costs and consequences of enhanced primary care for depression: systematic review of randomised economic evaluations.[see comment]. British Journal of Psychiatry. Oct. 2006;189:297-308. [pmid: 17012652].
76 Gunn J, Diggens J, Hegarty K, et al. A systematic review of complex system interventions designed to increase recovery from depression in primary care. BMC Health Services Research. 2006;6:88. [pmid: 16842629].
77 Skultety KM, Zeiss A. The treatment of depression in older adults in the primary care setting: an evidence-based review. Health Psychology. Nov. 2006;25(6):665-74. [pmid: 17100494].
78 Williams JW Jr, Gerrity M, Holsinger T, et al. Systematic review of multifaceted interventions to improve depression care. General Hospital Psychiatry. Mar–Apr. 2007;292(2):91-116. [pmid: 17336659].
79 Vergouwen AC, Bakker A, Katon WJ, et al. Improving adherence to antidepressants: a systematic review of interventions. Journal of Clinical Psychiatry. Dec. 2003;64(12):1415-20. [pmid: 14728101].
80 Downs SH, Black N. The feasibility of creating a checklist for the assessment of the methodological quality both of randomised and non-randomised studies of health care interventions. Journal of Epidemiology & Community Health. Jun. 1998;52(6):377-84. [pmid: 9764259].
81 Atkins D, Best D, Briss PA, et al. Grading quality of evidence and strength of recommendations. BMJ. Jun 19. 2004;328(7454):1490. [pmid: 15205295].
82 Levkoff SE, Chen H, Coakley E, et al. Design and sample characteristics of the PRISM-E multisite randomized trial to improve behavioral health care for the elderly. Journal of Aging & Health. Feb. 2004;16(1):3-27. [pmid: 14979308].
83 Clarke G, Debar L, Lynch F, et al. A randomized effectiveness trial of brief cognitive-behavioral therapy for depressed adolescents receiving antidepressant medication. Journal of the American Academy of Child & Adolescent Psychiatry. Sep. 2005;44(9):888-98. [pmid: 16113617].
84 Simon GE, Ludman EJ, Tutty S, et al. Telephone psychotherapy and telephone care management for primary care patients starting antidepressant treatment: a randomized controlled trial.[see comment]. JAMA. Aug 25. 2004;292(8):935-42. [pmid: 15328325].
85 Swindle RW, Rao JK, Helmy A, et al. Integrating clinical nurse specialists into the treatment of primary care patients with depression. International Journal of Psychiatry in Medicine. 2003;33(1):17-37. [pmid: 12906341].
86 Wells K. The design of Partners in Care: evaluating the cost-effectiveness of improving care for depression in primary care. Social Psychiatry & Psychiatric Epidemiology. Jan. 1999;34(1):20-9. [pmid: 10073117].
87 Hedrick SC, Chaney EF, Felker B, et al. Effectiveness of collaborative care depression treatment in Veterans' Affairs primary care.[see comment]. Journal of General Internal Medicine. Jan. 2003;18(1):9-16. [pmid: 12534758].
88 Katon W, Robinson P, Von Korff M, et al. A multifaceted intervention to improve treatment of depression in primary care. Archives of General Psychiatry. Oct. 1996;53(10):924-32. [pmid: 8857869].
89 Tutty S, Simon G, Ludman E. Telephone counseling as an adjunct to antidepressant treatment in the primary care system. A pilot study[see comment]. Effective Clinical Practice. Jul–Aug. 2000;3(4):170-8. [pmid: 11183432].
90 Roy-Byrne PP, Craske MG, Stein MB, et al. A randomized effectiveness trial of cognitive-behavioral therapy and medication for primary care panic disorder.[see comment]. Archives of General Psychiatry. Mar. 2005;62(3):290-8. [pmid: 15753242].
91 Price D, Beck A, Nimmer C, et al. The treatment of anxiety disorders in a primary care HMO setting. Psychiatric Quarterly. 2000;71(1):31-45. [pmid: 10736815].
92 Fortney JC, Pyne JM, Edlund MJ, et al. Design and implementation of the telemedicine-enhanced antidepressant management study. General Hospital Psychiatry. Jan–Feb. 2006;28(1):18-26. [pmid: 16377361].
93 Grypma L, Haverkamp R, Little S, et al. Taking an evidence-based model of depression care from research to practice: making lemonade out of depression.[see comment]. General Hospital Psychiatry. Mar–Apr. 2006;28(2):101-7. [pmid: 16516059].
94 Unutzer J, Katon W, Williams JW Jr, et al. Improving primary care for depression in late life: the design of a multicenter randomized trial. Medical Care. Aug. 2001;39(8):785-99. [pmid: 11468498].
95 Bruce ML, Pearson JL. Designing an intervention to prevent suicide: PROSPECT (Prevention of Suicide in Primary Care Elderly: Collaborative Trial). Dialogues in Clinical Neuroscience. 1999;1(2):100-12. [pmid: 22033641].
96 Oxman T, Dietrich A, Williams JJ, et al. A three-component model for reengineering systems for the treatment of depression in primary care. Psychosomatics. Nov–Dec. 2002;43(6):441-50. [pmid: 12444226].
97 Datto CJ, Thompson R, Horowitz D, et al. The pilot study of a telephone disease management program for depression. General Hospital Psychiatry. May–Jun. 2003;25(3):169-77. [pmid: 12748029].
98 Katon W, Rutter C, Ludman EJ, et al. A randomized trial of relapse prevention of depression in primary care. Archives of General Psychiatry. Mar. 2001;58(3):241-7. [pmid: 11231831].
99 Simon G, VonKorff M, Rutter C, et al. Randomised trial of monitoring, feedback, and management of care by telephone to improve treatment of depression in primary care.[see comment]. BMJ. Feb 26. 2000;320(7234):550-4. [pmid: 10688563].
100 Katzelnick D, Simon G, Pearson S, et al. Randomized trial of a depression management program in high utilizers of medical care.[see comment]. Archives of Family Medicine. Apr. 2000;9(4):345-51. [pmid: 10776363].
101 Rollman BL, Belnap BH, Mazumdar S, et al. A randomized trial to improve the quality of treatment for panic and generalized anxiety disorders in primary care. Archives of General Psychiatry. Dec. 2005;62(12):1332-41. [pmid: 16330721].
102 Katon W, Von Korff M, Lin E, et al. Collaborative management to achieve treatment guidelines. Impact on depression in primary care. JAMA. Apr 5. 1995;273(13):1026-31. [pmid: 7897786].
103 Katon W, Von Korff M, Lin E, et al. Stepped collaborative care for primary care patients with persistent symptoms of depression: a randomized trial. Archives of General Psychiatry. Dec. 1999;56(12):1109-15. [pmid: 10591288].
104 Boudreau DM, Capoccia KL, Sullivan SD, et al. Collaborative care model to improve outcomes in major depression. Annals of Pharmacotherapy. Apr. 2002;36(4):585-91. [pmid: 11918503].
105 Hilty DM, Marks S, Wegeland J, et al. A randomized, controlled trial of disease management modules, including telepsychiatric care, for depression in rural primary care. Psychiatry. Feb. 2007;4(2):58-65. [pmid: 20805900].
106 Adler DA, Bungay KM, Wilson IB, et al. The impact of a pharmacist intervention on 6-month outcomes in depressed primary care patients. General Hospital Psychiatry. May–Jun. 2004;26(3):199-209. [pmid: 15121348].
107 Katon W, Von Korff M, Lin E, et al. A randomized trial of psychiatric consultation with distressed high utilizers. General Hospital Psychiatry. Mar. 1992;14(2):86-98. [pmid: 1592254].
108 Finley PR, Rens HR, Pont JT, et al. Impact of a collaborative care model on depression in a primary care setting: a randomized controlled trial. Pharmacotherapy. Sep. 2003;23(9):1175-85. [pmid: 14524649].
109 Roy-Byrne PP, Katon W, Cowley DS, et al. A randomized effectiveness trial of collaborative care for patients with panic disorder in primary care.[see comment]. Archives of General Psychiatry. Sep. 2001;58(9):869-76. [pmid: 11545671].
110 Hunkeler EM, Meresman JF, Hargreaves WA, et al. Efficacy of nurse telehealth care and peer support in augmenting treatment of depression in primary care.[see comment][comment]. Archives of Family Medicine. Aug. 2000;9(8):700-8. [pmid: 10927707].
111 Rost K, Nutting PA, Smith J, et al. Designing and implementing a primary care intervention trial to improve the quality and outcome of care for major depression. General Hospital Psychiatry. Mar–Apr. 2000;22(2):66-77. [pmid: 10822094].
112 Epstein JN, Rabiner D, Johnson DE, et al. Improving attention-deficit/hyperactivity disorder treatment outcomes through use of a collaborative consultation treatment service by community-based pediatricians: a cluster randomized trial. Archives of Pediatrics & Adolescent Medicine. Sep. 2007;161(9):835-40. [pmid: 17768282].
113 Katon WJ, Von Korff M, Lin EH, et al. The Pathways Study: a randomized trial of collaborative care in patients with diabetes and depression.[see comment]. Archives of General Psychiatry. Oct. 2004;61(10):1042-9. [pmid: 15466678].
114 Asarnow JR, Jaycox LH, Duan N, et al. Effectiveness of a quality improvement intervention for adolescent depression in primary care clinics: a randomized controlled trial.[see comment]. JAMA. Jan 19. 2005;293(3):311-9. [pmid: 15657324].
115 Ludman E, Von Korff M, Katon W, et al. The design, implementation, and acceptance of a primary care-based intervention to prevent depression relapse. International Journal of Psychiatry in Medicine. 2000;30(3):229-45. [pmid: 11209991].
116 Case Management Society of America. Support & development of care management professionals. Available at: http://www.cmsa.org/ABOUTUS/DefinitionofCaseManagement/tabid/104/Default.aspx. Accessed March 27, 2008.
117 Brody DS, Hahn SR, Spitzer RL, et al. Identifying patients with depression in the primary care setting: a more efficient method. Archives of Internal Medicine. Dec 7–21. 1998;158(22):2469-75. [pmid: 9855385].
118 Krahn DD, Bartels SJ, Coakley E, et al. PRISM-E: comparison of integrated care and enhanced specialty referral models in depression outcomes. Psychiatric Services. Jul. 2006;57(7):946-53. [pmid: 16816278].
119 Watkins K, Pincus HA, Tanielian T. Evidence based care models for recognizing and treating alcohol problems in primary care settings. Santa Monica, CA: RAND Corporation; 200.
120 Dietrich AJ, Oxman TE, Williams JW Jr, et al. Re-engineering systems for the treatment of depression in primary care: cluster randomised controlled trial.[see comment]. BMJ. Sep 11. 2004;329(7466):602. [pmid: 15345600].
121 Unutzer J, Katon W, Callahan CM, et al. Collaborative care management of late-life depression in the primary care setting: a randomized controlled trial.[see comment]. JAMA. Dec 11. 2002;288(22):2836-45. [pmid: 12472325].
122 Sherbourne CD, Wells KB, Duan N, et al. Long-term effectiveness of disseminating quality improvement for depression in primary care. Archives of General Psychiatry. Jul. 2001;58(7):696-703. [pmid: 11448378].
123 Wells K, Sherbourne C, Schoenbaum M, et al. Impact of disseminating quality improvement programs for depression in managed primary care: a randomized controlled trial. JAMA. Jan 12. 2000;283(2):212-20. [pmid: 10634337].
124 Rost K, Nutting P, Smith J, et al. Improving depression outcomes in community primary care practice: a randomized trial of the QuEST intervention. Quality Enhancement by Strategic Teaming. Journal of General Internal Medicine. Mar. 2001;16(3):143-9. [pmid: 11318908].
125 Bruce M, Ten Have T, Reynolds Cr, et al. Reducing suicidal ideation and depressive symptoms in depressed older primary care patients: a randomized controlled trial. JAMA. Mar 3. 2004;291(9):1081-91. [pmid: 14996777].
126 Oslin DW, Grantham S, Coakley E, et al. PRISM-E: comparison of integrated care and enhanced specialty referral in managing at-risk alcohol use.[erratum appears in Psychiatr Serv. 2006 Oct;57(10):1492 Note: Olsen, Ed [added]; Kirchner, JoAnn E [added]; Levkoff, Sue [added]]. Psychiatric Services. Jul. 2006;57(7):954-8. [pmid: 16816279].
127 Schulberg HC, Post EP, Raue PJ, et al. Treating late-life depression with interpersonal psychotherapy in the primary care sector. International Journal of Geriatric Psychiatry. Feb. 2007;22(2):106-14. [pmid: 17096458].
128 Lin EH, Tang L, Katon W, et al. Arthritis pain and disability: response to collaborative depression care. General Hospital Psychiatry. Nov–Dec. 2006;28(6):482-6. [pmid: 17088163].
129 Lin EH, Katon W, Von Korff M, et al. Effect of Improving Depression Care on Pain and Functional Outcomes Among Older Adults With Arthritis: A Randomized Controlled Trial. JAMA: Journal of the American Medical Association. Nov. 2003;290(18):2428-34. [pmid: 14612479].
130 Callahan CM, Kroenke K, Counsell SR, et al. Treatment of depression improves physical functioning in older adults.[see comment]. Journal of the American Geriatrics Society. Mar. 2005;53(3):367-73. [pmid: 15743276].
131 Fortney JC, Pyne JM, Edlund MJ, et al. A randomized trial of telemedicine-based collaborative care for depression. Journal of General Internal Medicine. Aug. 2007;22(8):1086-93. [pmid: 17492326].
132 Schoenbaum M, Unutzer J, Sherbourne C, et al. Cost-effectiveness of practice-initiated quality improvement for depression: results of a randomized controlled trial. JAMA. Sep 19. 2001;286(11):1325-30. [pmid: 11560537].
133 Katon WJ, Roy-Byrne P, Russo J, et al. Cost-effectiveness and cost offset of a collaborative care intervention for primary care patients with panic disorder. Archives of General Psychiatry. Dec. 2002;59(12):1098-104. [pmid: 12470125].
134 Katon W, Russo J, Sherbourne C, et al. Incremental cost-effectiveness of a collaborative care intervention for panic disorder. Psychological Medicine. Mar. 2006;36(3):353-63. [pmid: 16403243].
135 Alexopoulos GS, Katz IR, Bruce ML, et al. Remission in depressed geriatric primary care patients: a report from the PROSPECT study. American Journal of Psychiatry. Apr. 2005;162(4):718-24. [pmid: 15800144].
136 Jaycox LH, Miranda J, Meredith LS, et al. Impact of a primary care quality improvement intervention on use of psychotherapy for depression. Mental Health Services Research. Jun. 2003;5(2):109-20. [pmid: 12801074].
137 Arean PA, Ayalon L, Hunkeler E, et al. Improving depression care for older, minority patients in primary care. Medical Care. Apr. 2005;43(4):381-90. [pmid: 15778641].
138 Adams SJ, Xu S, Dong F, et al. Differential effectiveness of depression disease management for rural and urban primary care patients. Journal of Rural Health. 2006;22(4):343-50. [pmid: 17010032].
139 Hegel MT, Unutzer J, Tang L, et al. Impact of comorbid panic and posttraumatic stress disorder on outcomes of collaborative care for late-life depression in primary care. American Journal of Geriatric Psychiatry. Jan. 2005;13(1):48-58. [pmid: 15653940].
140 Bogner HR, Bruce ML, Reynolds CF, III, et al. The effects of memory, attention, and executive dysfunction on outcomes of depression in a primary care intervention trial: The PROSPECT study: International Journal of Geriatric Psychiatry Vol 22(9) Sep 2007, 922–929; 2007.
141 Mavandadi S, Ten Have TR, Katz IR, et al. Effect of depression treatment on depressive symptoms in older adulthood: the moderating role of pain. Journal of the American Geriatrics Society. Feb. 2007;55(2):202-11. [pmid: 17302656].
142 Williams JW Jr, Katon W, Lin EH, et al. The effectiveness of depression care management on diabetes-related outcomes in older patients.[see comment]. Annals of Internal Medicine. Jun 15. 2004;140(12):1015-24. [pmid: 15197019].
143 Ciechanowski PS, Russo JE, Katon WJ, et al. The association of patient relationship style and outcomes in collaborative care treatment for depression in patients with diabetes. Medical Care. Mar. 2006;44(3):283-91. [pmid: 16501401].
144 Hinton L, Zweifach M, Oishi S, et al. Gender disparities in the treatment of late-life depression: qualitative and quantitative findings from the IMPACT trial. American Journal of Geriatric Psychiatry. Oct. 2006;14(10):884-92. [pmid: 17001028].
145 Zanjani F, Zubritsky C, Mullahy M, et al. Predictors of adherence within an intervention research study of the at-risk older drinker: PRISM-E. Journal of Geriatric Psychiatry & Neurology. Dec. 2006;19(4):231-8. [pmid: 17085763].
146 Kilbourne AM, Schulberg HC, Post EP, et al. Translating evidence-based depression management services to community-based primary care practices. Milbank Quarterly. 2004;82(4):631-59. [pmid: 15595945].
147 Gask L. Overt and covert barriers to the integration of primary and specialist mental health care. Social Science & Medicine. Oct. 2005;61(8):1785-94. [pmid: 15913862].
148 Von Korff M, Goldberg D. Improving outcomes in depression.[see comment]. BMJ. Oct 27. 2001;323(7319):948-9. [pmid: 11679372].
149 Bachman J, Pincus HA, Houtsinger JK, et al. Funding mechanisms for depression care management: opportunities and challenges. General Hospital Psychiatry. Jul–Aug. 2006;28(4):278-88. [pmid: 16814626].
150 Abt. Reimbursement of Mental Health Services in Primary Care Settings; 2006.
151 Goldberg RJ. Financial incentives influencing the integration of mental health care and primary care. Psychiatric Services. Aug. 1999;50(8):1071-5. [pmid: 10445657].
152 Frank RG, Huskamp HA, Pincus HA. Aligning incentives in the treatment of depression in primary care with evidence-based practice. Psychiatric Services. May. 2003;54(5):682-7. [pmid: 12719498].
153 Lee PW, Dietrich AJ, Oxman TE, et al. Sustainable impact of a primary care depression intervention. Journal of the American Board of Family Medicine: JABFM. Sep–Oct. 2007;20(5):427-33. [pmid: 17823459].
154 Barry CL, Frank RG. Commentary: an economic perspective on implementing evidence-based depression care. Administration & Policy in Mental Health. Jan. 2006;33(1):21-5. [pmid: 16215663].
155 Grazier KL, Klinkman MS. The economics of integrated depression care: the University of Michigan study. Administration & Policy in Mental Health. Jan. 2006;33(1):16-20. [pmid: 16215878].
Williams JW Jr, Rost K, Dietrich AJ, et al. Primary care physicians' approach to depressive disorders. Effects of physician specialty and practice structure.[see comment]. Archives of Family Medicine. Jan–Feb. 1999;8(1):58-67. [pmid: 9932074].
157 Pincus HA. Depression and primary care: drowning in the mainstream or left on the banks?. Journal of Managed Care Pharmacy. Mar. 2006;12(2 Suppl):3-9. [pmid: 16623601].
158 Rollman BL, Weinreb L, Korsen N, et al. Implementation of guideline-based care for depression in primary care. Administration & Policy in Mental Health. Jan. 2006;33(1):43-53. [pmid: 16215662].
159 Thomas MR, Waxmonsky JA, McGinnis GF, et al. Realigning clinical and economic incentives to support depression management within a medicaid population: the Colorado access experience. Administration & Policy in Mental Health. Jan. 2006;33(1):26-33. [pmid: 16215666].
160 Schulberg HC, Bryce C, Chism K, et al. Managing late-life depression in primary care practice: a case study of the Health Specialist's role. International Journal of Geriatric Psychiatry. Jun. 2001;16(6):577-84. [pmid: 11424166].
161 Liu CF, Fortney J, Vivell S, et al. Time allocation and caseload capacity in telephone depression care management. American Journal of Managed Care. Dec. 2007;13(12):652-60. [pmid: 18069908].
162 Blasinsky M, Goldman HH, Unutzer J. Project IMPACT: a report on barriers and facilitators to sustainability. Administration & Policy in Mental Health. Nov. 2006;33(6):718-29. [pmid: 16967339].
163 IMPACT. IMPACT - Evidence based depression care. Available at: http://impact-uw.org/. Accessed March 25.
164 U.S. Preventive Services Task Force. Screening for depression. In: Agency for Healthcare Research and Quality, ed; 2002.
165 Rollman B, Hanusa B, Gilbert T, et al. The electronic medical record A randomized trial of its impact on primary care physicians' initial management of major depression. Archives of Internal Medicine. Jan 22. 2001;161(2):189-97. [pmid: 11176732].
166 Bachman J. Pay for Performance in Primary and Specialty Behavioral Health Care: Two “Concept” Proposals. Professional Psychology: Research and Practice. Aug. 2006;37(4):384-8.
167 Feldman MD, Ong MK, Lee DL, et al. Realigning economic incentives for depression care at UCSF. Administration & Policy in Mental Health. Jan. 2006;33(1):34-8. [pmid: 16215664].
168 Fagan PJ, Schmidt CW Jr, Cook B. A model for managed behavioral health care in an academic department of psychiatry.[see comment]. Psychiatric Services. Apr. 2002;53(4):431-6. [pmid: 11919356].
169 Lambert D, Gale J, Bird D, et al. Medicaid managed behavioral health in rural areas.[see comment]. Journal of Rural Health. 2003;19(1):22-32. [pmid: 12585771].
170 Labby D, Spofford M, Robison J, et al. The economics of depression in primary care: de-fragmentation in the Oregon Medicaid market. Administration & Policy in Mental Health. Jan. 2006;33(1):39-42. [pmid: 16215665].
171 Willenbring M, Olson D. A randomized trial of integrated outpatient treatment for medically ill alcoholic men. Archives of Internal Medicine. Sep 13. 1999;159(16):1946-52. [pmid: 10493326].
172 Boardman JB. Health access and integration for adults with serious and persistent mental illness. Families, Systems, & Health. Spr. 2006;24(1):3-18.
173 Unutzer J, Tang L, Oishi S, et al. Reducing suicidal ideation in depressed older primary care patients.[see comment]. Journal of the American Geriatrics Society. Oct. 2006;54(10):1550-6. [pmid: 17038073].
174 Escobar JI, Gara MA, Diaz-Martinez AM, et al. Effectiveness of a time-limited cognitive behavior therapy type intervention among primary care patients with medically unexplained symptoms. Annals of Family Medicine. Jul–Aug. 2007;5(4):328-35. [pmid: 17664499].
175 Capoccia KL, Boudreau DM, Blough DK, et al. Randomized trial of pharmacist interventions to improve depression care and outcomes in primary care. American Journal of Health-System Pharmacy. Feb 15. 2004;61(4):364-72. [pmid: 15011764].
176 Schoenbaum M, Unutzer J, McCaffrey D, et al. The effects of primary care depression treatment on patients' clinical status and employment. Health Services Research. Oct. 2002;37(5):1145-58. [pmid: 12479490].
177 Rollman BL, Herbeck Belnap B, Reynolds CF, et al. A contemporary protocol to assist primary care physicians in the treatment of panic and generalized anxiety disorders. General Hospital Psychiatry. Mar–Apr. 2003;25(2):74-82. [pmid: 12676419].
178 Bungay KM, Adler DA, Rogers WH, et al. Description of a clinical pharmacist intervention administered to primary care patients with depression. General Hospital Psychiatry. May–Jun. 2004;26(3):210-8. [pmid: 15121349].
179 Grembowski DE, Martin D, Patrick DL, et al. Managed care, access to mental health specialists, and outcomes among primary care patients with depressive symptoms. Journal of General Internal Medicine. Apr. 2002;17(4):258-69. [pmid: 11972722].
180 Oslin DW. Late-life alcoholism: issues relevant to the geriatric psychiatrist. American Journal of Geriatric Psychiatry. Nov–Dec. 2004;12(6):571-83. [pmid: 15545325].
181 Rost K, Smith JL, Dickinson M. The effect of improving primary care depression management on employee absenteeism and productivity. A randomized trial. Medical Care. Dec. 2004;42(12):1202-10. [pmid: 15550800].
182 Lin EH, VonKorff M, Russo J, et al. Can depression treatment in primary care reduce disability? A stepped care approach. Archives of Family Medicine. Nov–Dec. 2000;9(10):1052-8. [pmid: 11115207].
183 Unutzer J, Rubenstein L, Katon WJ, et al. Two-year effects of quality improvement programs on medication management for depression. Archives of General Psychiatry. Oct. 2001;58(10):935-42. [pmid: 11576031].
184 Chen H, Coakley EH, Cheal K, et al. Satisfaction with mental health services in older primary care patients. American Journal of Geriatric Psychiatry. Apr. 2006;14(4):371-9. [pmid: 16582046].
185 Katon WJ, Schoenbaum M, Fan MY, et al. Cost-effectiveness of improving primary care treatment of late-life depression. Archives of General Psychiatry. Dec. 2005;62(12):1313-20. [pmid: 16330719].
186 Katon W, Unutzer J, Fan MY, et al. Cost-effectiveness and net benefit of enhanced treatment of depression for older adults with diabetes and depression. Diabetes Care. Feb. 2006;29(2):265-70. [pmid: 16443871].
187 Unutzer J, Katon WJ, Fan M-Y, et al. Long-term cost effects of collaborative care for late-life depression. American Journal of Managed Care. Feb. 2008;14(2):95-100. [pmid: 18269305].
188 Simon GE, Katon WJ, Lin EHB, et al. Cost-effectiveness of systematic depression treatment among people with diabetes mellitus.[see comment]. Archives of General Psychiatry. Jan. 2007;64(1):65-72. [pmid: 17199056].
189 Liu CF, Hedrick SC, Chaney EF, et al. Cost-effectiveness of collaborative care for depression in a primary care veteran population. Psychiatric Services. May. 2003;54(5):698-704. [pmid: 12719501].
190 Simon GE, Katon WJ, VonKorff M, et al. Cost-effectiveness of a collaborative care program for primary care patients with persistent depression. American Journal of Psychiatry. Oct. 2001;158(10):1638-44. [pmid: 11578996].
191 Von Korff M, Katon W, Bush T, et al. Treatment costs, cost offset, and cost-effectiveness of collaborative management of depression. Psychosomatic Medicine. Mar–Apr. 1998;60(2):143-9. [pmid: 9560861].
192 Simon GE, Von Korff M, Ludman EJ, et al. Cost-effectiveness of a program to prevent depression relapse in primary care. Medical Care. Oct. 2002;40(10):941-50. [pmid: 12395027].
193 Simon GE, Manning WG, Katzelnick DJ, et al. Cost-effectiveness of systematic depression treatment for high utilizers of general medical care.[see comment]. Archives of General Psychiatry. Feb. 2001;58(2):181-7. [pmid: 11177120].
194 Pyne JM, Rost KM, Zhang M, et al. Cost-effectiveness of a primary care depression intervention.[see comment]. Journal of General Internal Medicine. Jun. 2003;18(6):432-41. [pmid: 12823650].
195 Pyne J, Rost K, Farahati F, et al. One size fits some: the impact of patient treatment attitudes on the cost-effectiveness of a depression primary-care intervention. Psychological Medicine. Jun. 2005;35(6):839-54. [pmid: 15997604].
196 Dickinson L, Rost K, Nutting P, et al. RCT of a care manager intervention for major depression in primary care: 2-year costs for patients with physical vs psychological complaints. Annals of Family Medicine. Jan–Feb. 2005;3(1):15-22. [pmid: 15671186].
197 Rost K, Pyne J, Dickinson L, et al. Cost-effectiveness of enhancing primary care depression management on an ongoing basis. Annals of Family Medicine. Jan–Feb. 2005;3(1):7-14. [pmid: 15671185].
198 Bartels SJ, Coakley EH, Zubritsky C, et al. Improving access to geriatric mental health services: a randomized trial comparing treatment engagement with integrated versus enhanced referral care for depression, anxiety, and at-risk alcohol use.[see comment]. American Journal of Psychiatry. Aug. 2004;161(8):1455-62. [pmid: 15285973].
199 Arean PA, Gum AM, Tang L, et al. Service use and outcomes among elderly persons with low incomes being treated for depression. Psychiatric Services. Aug. 2007;58(8):1057-64. [pmid: 17664516].
200 Rost K, Adams S, Xu S, et al. Rural-urban differences in hospitalization rates of primary care patients with depression. Psychiatric Services. Apr. 2007;58(4):503-8. [pmid: 17412852].
201 Mittal D, Fortney JC, Pyne JM, et al. Impact of comorbid anxiety disorders on health-related quality of life among patients with major depressive disorder. Psychiatric Services. Dec. 2006;57(12):1731-7. [pmid: 17158487].
202 Bush T, Rutter C, Simon G, et al. Who benefits from more structured depression treatment?. International Journal of Psychiatry in Medicine. 2004;34(3):247-58. [pmid: 15666959].
203 Walker EA, Katon WJ, Russo J, et al. Predictors of outcome in a primary care depression trial.[see comment]. Journal of General Internal Medicine. Dec. 2000;15(12):859-67. [pmid: 11119182].
204 Roy-Byrne PP, Russo J, Cowley DS, et al. Unemployment and emergency room visits predict poor treatment outcome in primary care panic disorder. Journal of Clinical Psychiatry. Apr. 2003;64(4):383-9. [pmid: 12716237].
205 Kirkcaldy RD, Tynes LL. Depression screening in a VA primary care clinic. Psychiatric Services. Dec. 2006;57(12):1694-6. [pmid: 17158481].
206 Doolittle GC. Telemedicine in Kansas: the successes and the challenges. Journal of Telemedicine & Telecare. 2001;7(Suppl 2):43-6. [pmid: 11747656].
207 John R, Buschman P, Chaszar M, et al. Development and evaluation of a PDA-based decision support system for pediatric depression screening. Medinfo. 2007;12(Pt 2):1382-6.
208 Callahan CM, Boustani MA, Unverzagt FW, et al. Effectiveness of collaborative care for older adults with Alzheimer disease in primary care: a randomized controlled trial. JAMA. May 10. 2006;295(18):2148-57. [pmid: 16684985].
209 Quirk MP, Simon G, Todd J, et al. A look to the past, directions for the future. Psychiatric Quarterly. 2000;71(1):79-95. [pmid: 10736818].
210 Steinfeld B, Ekorenrud B, Gillett C, et al. EMRs bring all of healthcare together. Behavioral Healthcare. Jan. 2006;26(1):12-7. [pmid: 16669528].
211 Nutting PA, Gallagher KM, Riley K, et al. Implementing a depression improvement intervention in five health care organizations: experience from the RESPECT-Depression trial. Administration & Policy in Mental Health. Mar. 2007;34(2):127-37. [pmid: 16967338].
212 Reynolds K, Koster V. Innovative Ways to Finance Mental Health Services in a Primary Care Setting. Ypsilanti: Washtenaw Community Health Organization; 2005.
213 Sabourin D, Reynolds K. Raising the Bar: Moving Toward Integration of Healthcare. www.thenationalcouncil.org: National Council of Community Behavioral Health.
214 Grazier KL, Hegedus AM, Carli T, et al. Integration of behavioral and physical health care for a medicaid population through a public-public partnership. Psychiatric Services. Nov. 2003;54(11):1508-12. [pmid: 14600310].
215 Reynolds KM, Chesney BK, Capobianco J. A collaborative model for integrated mental and physical health care for the individual who is seriously and persistently mentally ill: The Washtenaw Community Health Organization. Families, Systems, & Health. Spr. 2006;24(1):19-27.
216 Reiss-Brennan B. Can mental health integration in a primary care setting improve quality and lower costs? A case study. Journal of Managed Care Pharmacy. Mar. 2006;12(2 Suppl):14-20. [pmid: 16623603].
217 Reiss-Brennan B, Briot P, Cannon W, et al. Mental health integration: rethinking practitioner roles in the treatment of depression: the specialist, primary care physicians, and the practice nurse. Ethnicity & Disease. 2006;16(2 Suppl 3):S3-37. 43. [pmid: 16774022].
218 Reiss-Brennan B, Oppenheim D, Kirstein JL. Rebuilding family relationship competencies as a primary health intervention. Primary Care Companion J Clin Psychiatry. 2002;4(0):1-13.
219 Reiss-Brennan B, Van Uitert D, Atkin Q. The Role of the Psychologist in Intermountain's Mental Health Integration Program. The Register Report. 2007;33:37-9.
220 Rubenstein LV, Meredith LS, Parker LE, et al. Impacts of evidence-based quality improvement on depression in primary care: a randomized experiment.[see comment]. Journal of General Internal Medicine. Oct. 2006;21(10):1027-35. [pmid: 16836631].
221 Dobscha SK, Corson K, Hickam DH, et al. Depression decision support in primary care: a cluster randomized trial.[see comment][summary for patients in Ann Intern Med. 2006 Oct 3;145(7):I10; PMID: 17015861]. Annals of Internal Medicine. Oct 3. 2006;145(7):477-87. [pmid: 17015865].
222 Hepner KA, Rowe M, Rost K, et al. The effect of adherence to practice guidelines on depression outcomes.[see comment]. Annals of Internal Medicine. Sep 4. 2007;147(5):320-9. [pmid: 17785487].
223 Gaynes BN, Rush AJ, Trivedi MH, et al. Primary versus specialty care outcomes for depressed outpatients managed with measurement-based care: results from STAR*D. J Gen Intern Med. May. 2008;23(5):551-60. [pmid: 18247097].
224 Fleming MF, Mundt MP, French MT, et al. Brief physician advice for problem drinkers: long-term efficacy and benefit-cost analysis.[see comment]. Alcoholism: Clinical & Experimental Research. Jan. 2002;26(1):36-43.
225 Drinka TJK, Clark PG. Health Care Teamwork: Interdisciplinary Practice and Teaching. Westport, CT: Greenwood Publishing Group; 2000.
226 ICSI. DIAMOND. Available at: http://www.icsi.org/news/diamond_news/.
227 Rost KM, Duan N, Rubenstein LV, et al. The Quality Improvement for Depression collaboration: general analytic strategies for a coordinated study of quality improvement in depression care. General Hospital Psychiatry. Sep–Oct. 2001;23(5):239-53. [pmid: 11600165].
228 Solberg LI. Improving medical practice: a conceptual framework. Annals of Family Medicine. May–Jun. 2007;5(3):251-6. [pmid: 17548853].
229 Trivedi MH, Rush AJ, Crismon ML, et al. Clinical results for patients with major depressive disorder in the Texas Medication Algorithm Project. Archives of General Psychiatry. Jul. 2004;61(7):669-80. [pmid: 15237079].
230 Fink P, Rosendal M, Toft T. Assessment and treatment of functional disorders in general practice: the extended reattribution and management model—an advanced educational program for nonpsychiatric doctors. Psychosomatics. Mar–Apr. 2002;43(2):93-131. [pmid: 11998587].
231 Morriss RK, Gask L. Treatment of patients with somatized mental disorder: effects of reattribution training on outcomes under the direct control of the family doctor. Psychosomatics. Sep–Oct. 2002;43(5):394-9. [pmid: 12297608].
232 Salmon P, Ring A, Dowrick CF, et al. What do general practice patients want when they present medically unexplained symptoms, and why do their doctors feel pressurized?. Journal of Psychosomatic Research. Oct. 2005;59(4):255-60. discussion 61–2. [pmid: 16223629].
233 Salmon P, Humphris GM, Ring A, et al. Primary care consultations about medically unexplained symptoms: patient presentations and doctor responses that influence the probability of somatic intervention. Psychosomatic Medicine. Jul–Aug. 2007;69(6):571-7. [pmid: 17636151].
234 Salmon P, Humphris GM, Ring A, et al. Why do primary care physicians propose medical care to patients with medically unexplained symptoms? A new method of sequence analysis to test theories of patient pressure.[see comment]. Psychosomatic Medicine. Jul–Aug. 2006;68(4):570-7. [pmid: 16868266].
235 Fink P, Rosendal M. Recent developments in the understanding and management of functional somatic symptoms in primary care. Current Opinion in Psychiatry. Mar. 2008;21(2):182-8. [pmid: 18332668].
236 Bauer MS, McBride L, Williford WO, et al. Collaborative care for bipolar disorder: part I. Intervention and implementation in a randomized effectiveness trial.[see comment]. Psychiatric Services. Jul. 2006;57(7):927-36. [pmid: 16816276].
237 Simon GE, Ludman E, Unutzer J, et al. Design and implementation of a randomized trial evaluating systematic care for bipolar disorder. Bipolar Disorders. 2002;4(4):226-36. [pmid: 12190711].
238 Aetna. Aetna Behavioral Health Introduces Industry-first Bipolar Disease Management Program. Available at: http://www.aetna.com/news/2006/pr_20061211.htm. Accessed March 25, 2008.
239 Park Nicollet Methodist Hospital. Eating Disorders Institute. Available at: http://www.parknicollet.com/Methodist/edi/. Accessed March 25.
240 Stuck AE, Siu AL, Wieland GD, et al. Comprehensive geriatric assessment: a meta-analysis of controlled trials. The Lancet. 1993;342:1032-6.
241 Cohen HJ, Feussner JR, Weinberger M, et al. A controlled trial of inpatient and outpatient geriatric evaluation and management. New England Journal of Medicine. 2002;346(12):905-12. [pmid: 11907291].
242 Barr M, Ginsburg J. The advanced medical home: A patient-centered, physician-guided model of health care. Philadelphia: A Policy Monograph of the American College of Physicians; 2006.
243 Kathol RG, Melek S, Bair B, et al. Financing mental health and substance use disorder care within physical health: a look to the future. Psychiatr Clin North Am. Mar. 2008;31(1):11-25. [pmid: 18295035].
244 Mims S. A sustainable behavioral health program integrated with public health primary care. Journal of Public Health Management Practice. Sep–Oct. 2006;12(5):456-61. [pmid: 16912608].
245 Carbone LA, Barsky AJ, Orav EJ, et al. Psychiatric symptoms and medical utilization in primary care patients. Psychosomatics. Nov–Dec. 2000;41(6):512-8. [pmid: 11110115].
246 Huyse F, Stiefel F. Medical Clinics of North America: Integrated Care for the Complex Medically Ill. Vol 90. Philadelphia: Elsevier; 2006.
247 First M, Spitzer R, Gibbon M, et al. Structured Clinical Interview for DSM-IV Clinical Version (SCID-I/CV). Washington DC: American Psychiatric Press; 1997.
248 Davidoff F, Batalden P. Toward stronger evidence on quality improvement. Draft publication guidelines: the beginning of a consensus project.[see comment]. Quality & Safety in Health Care. Oct. 2005;14(5):319-25. [pmid: 16195563].
249 Kessler RC, Demler O, Frank RG, et al. Prevalence and treatment of mental disorders, 1990 to 2003.[see comment]. New England Journal of Medicine. Jun 16. 2005;352(24):2515-23. [pmid: 15958807].
250 Kathol RG, McAlpine D, Kishi Y, et al. General medical and pharmacy claims expenditures in users of behavioral health services. Journal of General Internal Medicine. Feb. 2005;20(2):160-7. [pmid: 15836550].
251 Thomas MR, Waxmonsky JA, Gabow PA, et al. Prevalence of psychiatric disorders and costs of care among adult enrollees in a Medicaid HMO. Psychiatric Services. Nov. 2005;56(11):1394-401. [pmid: 16282258].