# Results

## Search Results

A summary of the search results is presented in Figure 2. We retrieved 1,110 unique citations from the search. After review of titles, abstracts, and full articles when necessary, we identified 33 studies and 145 companion articles that tested for the impact of integrating mental health and primary care on outcomes. Appendix E provides an evidence table for all relevant trials. However, if an article reported the study design but the study is otherwise ongoing and results beyond baseline characteristics have not been reported, that study is not included in the analyses. Excluded references are shown in Appendix F.

Figure 2. QUORUM Statement Data

The results for the key questions are divided into several sections. First we address studies that integrated mental health services into primary care. In the second part we examine efforts to bring primary care into mental health settings. The third section will present findings from the case studies.

## Integrating Mental Health into Primary Care

### Key Question 1: What Models have been Used? What is the Evidence that Integrated Care Leads to Better Outcomes?

Levels of integration of providers. Table 3 identifies how each of the studies assessed was classified into one of four levels of integration based on the two integration parameters.

Table 3 Level of integration of providers

Project Name or Author, Year | Decision Making | Location
High Level Integrated Providers
Price, 2000 ^91^ | Consensus | On-site
Katon, 1992 ^107^ | Consensus | On-site
Katon, 1995 ^102^ | Consensus | On-site
Katon, 1999 ^103^ | Consensus | On-site
Hedrick, 2003 ^87^ | Consensus | On-site
Swindle, 2003 ^85^ | Consensus | On-site
Intermediate I Level Integrated Providers
IMPACT ^2,^ ^94,^ ^121,^ ^130,^ ^173^ | Coordinated | On-site
Grypma, 2006 ^93^ | Coordinated | On-site
Pathways ^69,^ ^113^ | Coordinated | On-site
Katon, 1996 ^88^ | Coordinated | On-site
Katon, 2001 ^98^ | Coordinated | On-site
Roy-Byrne, 2001 ^109^ | Coordinated | On-site
Intermediate II Level Integrated Providers
Clarke, 2005 ^83^ | Coordinated | Unclear
Simon, 2004 ^84^ 2 arm | Coordinated | Separate
Escobar, 2007 ^174^ | Coordinated | Unclear
Epstein, 2007 ^112^ | Coordinated | Separate
Boudreau, 2002 ^104,^ ^175^ | Coordinated | Separate
Simon, 2004 ^84^ 1 arm | Coordinated | Separate
Finley, 2003 ^108^ | Coordinated | Separate
Hilty, 2007 ^105^ | Coordinated | Separate
CCAP ^9,^ ^90^ | PCP directed | On-site
PROSPECT ^95,^ ^125,^ ^135^ | PCP directed | On-site
PIC Therapy ^86,^ ^122,^ ^123,^ ^136,^ ^176^ | PCP directed | On-site
Asarnow, 2005 ^114^ | PCP directed | On-site
Low Level Integrated Providers
Tutty, 2000 ^89^ | PCP directed | Separate
Rollman, 2005 ^101,^ ^177^ | PCP directed | Separate
Hunkeler, 2000 ^110^ | PCP directed | Separate
Fortney, 2006 ^92,^ ^131^ | PCP directed | Telemed
Adler, 2004 ^106,^ ^178^ | PCP directed | Separate
QuEST ^5,^ ^111,^ ^124^ | PCP directed | Separate
Datto, 2003 ^97^ | PCP directed | Separate
RESPECT-D ^96,^ ^120^ | PCP directed | Separate
Katzelnick, 2000 ^100^ | PCP directed | Separate
Simon, 2000 ^99^ | PCP directed | Separate
PIC Med ^86,^ ^122,^ ^123,^ ^136,^ ^176^ | PCP directed | Separate

If care manager is high level, provided, and on location, coded as on-site. If care manager is low level and all other therapy is provided by referral, coded as separate.

Levels of integrated care process and proactive followup. Table 4 identifies how each of the studies assessed was classified into the integration terciles based on the composite process score.

Table 4 Level of integrated proactive process of care

Care Process Elements
Outcome Author | Screening | Patient Education/Self-Management | Medication | Psychotherapy | Coordinate Care | Clinical Monitoring | Medication Adherence | Standardized Followup | Formal Stepped Care | Supervision
High Integrated Process of Care
Fortney, 2006 ^92^ | Yes | 2 | Yes | No | Yes | Yes | Yes | Yes | Yes | Yes
Grypma, 2006 ^93^ | No | 2 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes
IMPACT ^2,^ ^94,^ ^121,^ ^130,^ ^173^ | Yes | 2 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes
Clarke, 2005 ^83^ | No | 2 | Yes | Yes | No | Yes | Yes | Yes | Yes | Yes
PROSPECT ^95,^ ^125,^ ^135^ | Yes | 2 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | NR
Pathways ^69,^ ^113^ | Yes | 2 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes
PIC-Med ^86,^ ^122,^ ^123,^ ^136,^ ^176^ | Yes | 1 | Yes | No | Yes | Yes | Yes | Yes | Yes | Yes
Hedrick, 2003 ^87^ | Yes | 2 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes
Katon, 1996 ^88^ | No | 2 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | NA
Katon, 2001 ^98^ | No | 2 | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes
CCAP ^9,^ ^90^ | Yes | 2 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes
Rollman, 2005 ^101,^ ^177^ | Yes | 2 | Yes | No | Yes | Yes | Yes | Yes | Yes | Yes
Price, 2000 ^91^ | Yes | 2 | Yes | Yes | Yes | Yes | Yes | No | Yes | NA
Asarnow, 2005 ^114^ | Yes | 2 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | NR
Intermediate Integrated Process of Care
RESPECT-D ^96,^ ^120^ | No | 1 | Yes | No | Yes | Yes | Yes | Yes | No | Yes
Simon, 2004 ^84^ arm 1 | No | 1 | Yes | No | Yes | Yes | Yes | Yes | No | Yes
Simon, 2004 ^84^ arm 2 | No | 1 | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes
Adler, 2004 ^106^ | Yes | 1 | Yes | No | Yes | Yes | Yes | Yes | No | Yes
Swindle, 2003, ^85^ | Yes | 0 | Yes | No | Yes | Yes | Yes | Yes | Yes | Yes
Datto, 2003 ^97^ | No | 2 | Yes | No | Yes | Yes | Yes | Yes | No | Yes
Boudreau, 2002 ^104,^ ^175^ | No | 0 | Yes | No | Yes | Yes | Yes | Yes | Yes | Yes
Tutty, 2000 ^89^ | No | 2 | Yes | Yes | No | Yes | Yes | No | No | NA
QuEST ^5,^ ^111,^ ^124^ | Yes | 1 | Yes | No | No | Yes | Yes | Yes | Yes | Yes
Hilty, 2007 ^105^ | No | 1 | Yes | No | Yes | Yes | Yes | Yes | NR | NR
Katzelnick, 2000 ^100^ | No | 1 | Yes | No | Yes | Yes | Yes | Yes | Yes | No
Roy-Byrne, 2001 ^109^ | Yes | 1 | Yes | No | No | No | Yes | Yes | Yes | NA
Low Integrated Process of Care
Finley, 2003 ^108^ | No | 1 | Yes | No | No | Yes | Yes | Yes | No | Yes
PIC therapy ^86,^ ^122,^ ^123,^ ^136,^ ^176^ | Yes | 1 | No | Yes | No | Yes | No | No | Unclear | Yes
Katon, 1995 ^102^ | No | 2 | Yes | No | No | No | Yes | Yes | No | NA
Katon, 1999 ^103^ | No | 1 | Yes | No | No | No | Yes | Yes | No | NA
Hunkeler, 2000 ^110^ | No | 0 | Yes | No | No | No | Yes | Yes | No | Yes
Simon, 2000 ^99^ | No | 0 | Yes | No | Yes | No | Yes | Yes | No | Yes
Katon, 1992 ^107^ | No | 0 | Yes | No | No | No | No | No | No | NA
Epstein, 2007 ^112^ | No | 0 | Yes | No | No | Yes | Yes | No | No | NA

Screen - since many took place under research conditions, coded as “yes” if the tools used were ones already, or easily, implemented in PC settings

Matrix integration. The matrix in Figure 3 reveals an imbalance in cell population. Only two studies are high in both parameters. A few cells have only one or no studies.

Figure 3. Matrix Integration

One study could not be incorporated into this review's operational definitions of integration. PRISM-E used a research design in which clinic eligibility for enrollment was based on meeting definitional criteria for integrated or enhanced referral care. ^82^ The clinics followed a standardized study protocol across sites, however, clinics were allowed some variation in care processes to meet location conditions. The reports do not provide detailed information or results at clinic levels necessary for inclusion in levels of integration analysis. Because of PRISM-E's unique study design, it will be discussed separately later in the section.

Each of the integration scores, separately and combined, was used to assess the relationship with potential outcomes of integrated care. Those outcomes include severity of mental illness symptoms, treatment response rates, and remission rates. Results for the Partners in Care project were reported in matrix cell 9 if the results for the therapy and medication treatment arms were not reported separately.

Data analysis. Only depression disorder studies were included in data analysis, due to the limited number of articles representing other mental health disorders. Data abstracted from articles comparing interventions to usual care were entered into an Excel table and analyzed using Stata 9.0. Odds ratios (OR) and confidence intervals (CI) were calculated for categorical data using reported counts, or ORs when provided. Mean differences and CIs were calculated for continuous data using group means and standard deviations. Data was not pooled due to significant heterogeneity. Unfortunately, a number of trials reported results as time trends, which could not be included in the analysis. Other articles did not supply sufficient information for calculations. While trials with nonsignificant findings can always be included in analysis by inputting nonsignificant but mathematically correct numbers, we included only trials that reported useable data. There were also a number of articles reporting significant findings that did not report the data in a form usable in the analysis. The evidence tables do report the outcomes for all studies. The results are displayed in groups of six month intervals. If a single trial reported more than one result within a six-month period, the result closest to the end of the period was reported.

Results for Key Question 1 are limited to the most commonly used clinical outcomes of interest, symptom severity, treatment response, and remission. Comprehensive reporting of outcomes, including functioning, quality of life, utilization, and costs, by mental health illness category, is provided in the results section for Key Question 4.

Models of integration. We identified 32 trials that examined the impact of integrating mental health specialists into primary care. The majority of these studies (N=25) addressed depression care, and four studies addressed anxiety disorders. The remaining studies were single studies for somatizing disorders, ADHD, and one study addressed both depression and alcohol-related disorders. The search did identify several studies of integrated care for addiction disorders; however, since the studies did not adequately report separate results for alcohol disorders alone, they were not included in the review. The included trials were reviewed for characteristics of provider integration, elements of the care process, and a description of the care manager role, if one was used, to provide an overview of the operational models of integrated care in use.

Provider integration. As mentioned previously, the key to integration is the linkage between primary care and specialty mental health providers. Table 5 details how the studies operationalized integration of providers. The providers involved varied widely, although all models included a psychiatrist or clinical psychologist who minimally was available for consultation. Some models assigned mental health therapists, who could be a doctorate or master's level psychologist, a clinical nurse with behavioral health training and experience, or a social worker. ^83^ – ^91^ Many models incorporated a care manager whose duties included acting as a communication link between the primary care and specialty mental health providers. ^69,^ ^86,^ ^92^ – ^101^ (More detail on the care manager roles and functions, including communication with patients, is provided later in this section.)

Table 5 Characteristics of integration programs for mental health into primary care

Outcome Project Name or Author | Case Identification | Providers Involved | Communication Methods | MH Location | Shared Medical Records | Decisionmaking
Depression Disorders
Fortney, 2006 ^92,^ ^131^ | Recruitment screening by PHQ-9 | PCP, care manager, pharmacist, consult telepsychiatrist, supervisory psychiatrist | Electronic medical record recommendations and progress notes, interactive video with PCP, weekly face-to-face meetings with care manager, pharmacist, and psychiatrist. Care manager as link. | Separate, linked by telemedicine technology | Yes | Team recommendations, PCP directed
Grypma, 2006 ^93^ | Referral | PCP, disease care manager, consulting psychiatrist | Care manager reviewed cases weekly with team psychiatrist and expert PCP. Unclear how communicated to PCP. Care manager as link. | Co-located | Yes | Care manager coordinates care with PCP
IMPACT ^2,^ ^94,^ ^121,^ ^130,^ ^173^ | 50% by referral, 50% by screening by PRIME-MD items | PCP, care manager, supervisory psychiatrist, expert PCP | Web-based tracking system. Care manager reviewed cases weekly with team psychiatrist and expert PCP. Unclear how communicated to PCP. Care manager as link. | PST on-site, Stepped referral care unclear | Yes | Care manager coordinates care with PCP
Clarke, 2005 ^83^ | None | PCP, research trained therapist, who also provided case management | Occasional consult between PCP and therapist. | Unclear | Yes (HMO) | Therapist coordinated with PCP
PROSPECT ^95,^ ^125,^ ^135,^ ^160^ | Recruitment screening by CES-D | PCP, care manager, supervising psychiatrist | Care manager and psychiatrist review cases weekly. Formal and informal care manager and PCP contact. Care manager as link. | Separate, care manager on site | Unclear | PCP directed
Pathways ^69,^ ^113^ | Recruitment screening by PHQ-9 | PCP, care manager, psychiatrist, psychologist | Care manager, psychiatrist, psychology team reviewed cases bi-weekly. Formal and informal care manager and PCP contact. Care manager as link. | Co-located. Stepped care referral separate | No, but shared monitoring system | Care manager coordinates care with PCP
RESPECT-D ^96,^ ^120^ | Referral | PCP, care manager, consulting psychiatrist | Care manager and psychiatrist reviewed cases weekly. PCP received written care management report forms. Consulting psychiatrist as liaison between referral care and PCP. | Separate, care manager on site. | Unclear | PCP directed
Simon, 2004 ^84^ | None (Recruitment by computerized pharmacy and visit registry records) | Treatment 1: PCP, care manager, supervising psychiatrist/psychologist | Care manager and psychiatrist reviewed cases weekly. PCP received structured report and computer generated recommendations. Care manager contacted PCP for treatment changes. | Separate, linked by telemedicine technology | Unclear | Care manager coordinates care with PCP. PCP directed
Treatment 2: PCP, care manager, therapist, supervising psychiatrist/psychologist | Care manager and psychiatrist reviewed cases weekly. Therapist not in contact with PCP. Care manager contacted PCP for treatment changes. PCP received structured report and computer generated recommendations. | Separate, linked by telemedicine technology | Unclear | Care manager coordinates care with PCP. PCP directed
Adler, 2004 ^106,^ ^178^ | Recruitment screening by PC-SAD | PCP, clinical pharmacist, consulting psychiatrist available | Pharmacist provided formal computer report to PCP. | Separate, pharmacist on site | No | PCP directed
Finley, 2003 ^108^ | Referral | PCP, clinical pharmacist, supervising psychiatrist | Pharmacist and psychiatrist reviewed cases weekly. Pharmacist consulted PCP regarding medication change. Progress reports to medical records. | Separate, pharmacist on-site | Unclear | Pharmacist and PCP within defined roles
Swindle, 2003 ^85^ | Recruitment screening by PRIME-MD | PCP, clinical nurse specialist, consulting psychiatrist | PCP and CNS develop and present treatment plan to patient. Warm hand-off if CBT referral. | Co-located | Unclear | PCP and CNS within defined roles
Partners in Care ^86,^ ^122,^ ^123,^ ^136,^ ^176^ | Recruitment screening by CIDI | QI meds: PCP, care manager, nurse supervisor, psychiatrist, expert PCP | Monthly expert team meetings and case review. Care manager provided written reports to PCP. | Separate, care manager on-site | Unclear | PCP directed
QI therapy: PCP, therapist, therapy supervisor, psychiatrist, expert PCP | Monthly expert team meetings and case review. Therapist provided written reports to PCP. | Co-located CBT, separate for warm hand-off referral | Unclear | PCP directed
Datto, 2003 ^97^ | Referral | PCP, care manager, supervising psychiatrist | Care manager faxed assessment letters and scores to PCP. PCP consulted with supervising psychiatrist as needed. | Separate, linked by telemedicine technology | No | PCP directed
Hedrick, 2003 ^87^ | Both screening and referral | PCP, social worker clinical psychologist, psychiatrist, psychology technician | Regular team meetings, electronic medical records with alert system. Team psychiatrist contacted PCP for treatment plan consensus. | Co-located | Yes | Consensus. Psychiatrist would write scrip if PCP did not.
Katon, 1995 ^102^ | None | PCP, psychiatrist | Monthly case conferences and consultation between PCP and psychiatrist. Verbal consult followed by consult letter within one week. | Co-located | Not reported, HMO | Consensus
Katon, 1999 ^103^ | None | PCP, psychiatrist | Monthly case conferences and consultation between PCP and psychiatrist. Verbal consult followed by consult letter within one week. | Co-located | Not reported, HMO | Consensus
Katon, 1996 ^88^ | None | PCP, psychologist, consulting psychiatrist | Case-by-case consultation between PCP and psychologist. Weekly meetings between psychiatrist and psychologist. Psychologist as link between psychiatrist and PCP. | Co-located | Not reported, HMO | Collaborative, manualized
Katon, 2001 ^98,^ ^115^ | None | PCP, depression specialist, study psychiatrist | PCP received intermittent verbal and written updates on patient progress from depression specialist. (Patient in maintenance phase) | Co-located | Not reported, HMO | Collaborative
Boudreau, 2002 ^104,^ ^175^ | Referral | PCP clinical pharmacist, study psychiatrist | Bi-monthly conferences between psychiatrist and pharmacist. Medication changes communicated to PCP. | Separate, pharmacist on-site | Yes | PCP directed, pharmacist for med changes
Tutty, 2000 ^89^ | None | PCP, psychotherapist who also provided case management | Computer generated reports and treatment algorithms provided to PCP and therapist. | Separate | Not reported, HMO | PCP directed
Hunkeler, 2000 ^110^ | Referral | PCP, telehealth nurse, supervising psychologist | Nurse reported patient progress to PCP, method not reported. No reported communication. | Not reported | Not reported | PCP directed
QuEST ^5,^ ^111,^ ^124^ | 2-stage recruitment screening by staff | PCP, clinic nurse, consulting psychiatrist (never utilized) | No communication between behavioral health and PCP noted. | Separate | No | PCP directed
Simon, 2000 ^99^ arm 1 Feedback only | Computerized pharmacy records | PCP | PCP received computer generated feedback with visits and medication history and algorithm based treatment recommendations. | Separate | Not reported, single HMO | PCP directed
Simon, 2000 ^99^ arm 2 Feedback and care management | Computerized pharmacy records | PCP, care manager, supervising psychiatrist | PCP received computer generated feedback with visits and medication history and algorithm based treatment recommendations. Care manager as link. | Separate | Not reported, single HMO | PCP directed
Hilty, 2007 ^105^ | Referral | PCP, telemedicine coordinator, consulting psychiatrist | PCP and psychiatrist held case reviews, psychiatrist trained PCP on guidelines, coordinator role not reported. | Separate, telemedicine | Not reported | PCP and psychiatrist collaborated on initial care plan
Katzelnick, 2000 ^100^ | Recruitment screening with CES-D | PCP, care manager, consulting psychiatrist | PCP and study psychiatrist held periodic case reviews, telephone consultations, PCP received written updates of care monitoring, care manager contacted by phone if patient not doing well. | Not reported | Not reported, HMOs | PCP directed
Asarnow, 2005 ^114^ | Recruitment screening by brief written CIDI questionnaire and CES-D | PCP, care manager, expert leader quality improvement team for consultation | PCP approved treatment plan created by care manager; methods of communication not reported | On-site | Not reported | PCP directed
Anxiety Disorders
Rollman, 2005 ^101,^ ^177^ | Recruitment screening by PRIME-MD | PCP, care manager, supervisory psychiatrist | Electronic medical record for treatment and progress notes. Care manager and psychiatrist review cases weekly. Care manager as link. | Unclear | Yes | PCP free to reject recommendations
CCAP ^9,^ ^90^ | Both screening by DSM-IV and referral | PCP, research trained therapist who also provided care management, supervising psychiatrist | Therapist and psychiatrist review cases weekly. Written communication by therapist to PCP. Therapist as link. | Co-located | No | PCP directed
Roy-Byrne, 2001 ^109^ | Recruitment screening by DSM-IV | PCP, psychiatrist | PCP received consultation letter after each psychiatric visit. | Unclear | Not reported | Psychiatrist led
Price, 2000 ^91^ | PCP screened and referred | PCP, clinical psychologist, consulting psychiatrist available | Psychologist met with PCP in formal department meetings and informal “curbside” meetings, joint meetings with patient | Co-located | Not reported, single HMO | Consensus
Other Disorders
Katon, 1992 ^107^ | Recruitment screening | PCP, research psychiatrist | PCP and psychiatrist met with patient as team. Consult letters and meetings. | Co-located | Not reported, single HMO | Consensus
Epstein, 2007 ^112^ | Referral | PCP, research psychiatrists | Consultation reports | Separate | No | PCP directed

Other forms of communication links between providers ranged from consultations on an as-needed basis ^83,^ ^97^ to regularly scheduled case reviews ^69,^ ^84,^ ^86^ – ^88,^ ^90,^ ^92^ – ^96,^ ^100^ – ^105^ and formal protocols for updating primary care providers on patient progress. ^69,^ ^84,^ ^86,^ ^89,^ ^90,^ ^92,^ ^95,^ ^96,^ ^98^ – ^101,^ ^106^ These updates were provided in the form of computer generated reports, notes and flags in electronic medical records, standardized reports from care managers, or updating consultation letters following patient treatment by a mental health provider. Noted is the lack of information on whether communication linkages included specific training of medical and mental health providers' interpersonal collaborative skills.

Co-located services are intended to facilitate care coordination and communication between providers as well as increase access for patients. Published reports did not always clearly report the location of mental health services. Of those that did, the majority either co-located mental health providers or behavioral health trained care managers in the primary care site ^69,^ ^85^ – ^88,^ ^90,^ ^91,^ ^93,^ ^94,^ ^98,^ ^102,^ ^103,^ ^107^ or used telemedicine technology to bring otherwise unavailable services to rural or small clinic settings. ^84,^ ^92,^ ^97,^ ^105^

Shared medical records provide a common information base to involved providers, a systematic level of integration. Unfortunately, published reports that included specific information on shared medical records were scarce. Only seven trials clearly stated that providers shared medical records. ^83,^ ^87,^ ^92^ – ^94,^ ^101,^ ^104^ Single HMOs were the settings for another nine trials, ^88,^ ^89,^ ^91,^ ^98^ – ^100,^ ^102,^ ^103,^ ^107^ which might imply improved access to medical records by providers, but this remains speculation without further documentation.

Decisionmaking processes operationalize the nature of the relationship between the medical and mental health providers. Wulsin et al. describe seven relationship levels ranging from completely autonomous to a fully integrated team that provides comprehensive care. ^52^ The trials fell into three patterns of decisionmaking used by providers. The majority of trials were evenly split between coordinated decisionmaking practices ^69,^ ^83,^ ^84,^ ^88,^ ^93,^ ^94,^ ^98,^ ^105,^ ^108,^ ^109^ and the primary care provider principally responsible for care, with the assistance of care management and specialty mental health providers as support ^86,^ ^92,^ ^95,^ ^96,^ ^106,^ ^89,^ ^90,^ ^97,^ ^99^ – ^101,^ ^104,^ ^110^ – ^112^ Only five trials reported consensus decisionmaking between medical and mental health providers. ^87,^ ^91,^ ^102,^ ^103,^ ^107^

Systematic screening. As shown in Table 5, half of the studies integrating specialty mental care into primary care included a method of systematic screening for mental health problem. ^69,^ ^82,^ ^85^ – ^87,^ ^90^ – ^92,^ ^94,^ ^95,^ ^101,^ ^106,^ ^107,^ ^109,^ ^111^ The remaining studies either relied only on referrals from the PCP ^93,^ ^96,^ ^97,^ ^104,^ ^105,^ ^108,^ ^110,^ ^112^ or were targeted toward all patients starting treatment for a mental health problem, such as antidepressant medication treatment. ^83,^ ^84,^ ^88,^ ^89,^ ^98,^ ^99,^ ^102,^ ^103^ A variety of tools were used by those studies that employed screeners; no single screener predominated.

Integrated process of care. Integrated care provides a structure within which the process of care is enacted. Table 6 details how studies operationalized common elements of an integrated process of care. These elements included patient collaboration features, provision of limited psychotherapy, and systematic followup.

Table 6 Elements of care process

Outcome Project Name or Author | Screening | Patient Education of Condition | Patient Self-management Skills | Psychotherapy | Mental Health Specialist Involvement | Clinical and Adherence Monitoring | Standardized Followup | Formal Stepped Care
Depression Disorders
Fortney, 2006 ^92,^ ^131^ | Yes | Patient and care manager | Care manager | By referral | Tele-psychiatrist, available for PCP consult | Care manager, clinical, medication adherence | Yes, scripted, 12 months | Yes
Grypma, 2006 ^93^ | Not reported | Care manager, optional group education by HMO patient education department | Care manager | 6 to 8 PST sessions by care manager | Psychiatrist, available for consult | Care manager, PHQ9 clinical | Yes, based on patient's self-determined need | Yes
IMPACT ^2,^ ^94,^ ^121,^ ^130,^ ^173^ | 2 item from PRIME-MD | Care manager | Care manager | 6 to 8 PST sessions by care manager | Psychiatrist, available for consult | Care manager, PHQ9 clinical | Yes, 12 months | Yes
Clarke, 2005 ^83^ | No | Therapist | Therapist | Up to 9 60-minute CBT sessions | Mental health therapist, provide CBT, consult with PCP | Mental health provider, clinical, medication adherence | Yes, 9 months | Yes
PROSPECT ^95,^ ^125,^ ^135^ | CESD | Care manager | Care manager | IPT | Nurse, social worker, or clinical psychologist, provide IPT and care management | Care manager, clinical and adherence | Yes, unclear | Yes
Pathways ^69,^ ^113^ | Mailed screen, PHQ | Care manager | Care manager | 6 to 8 PST sessions by care manager | Psychiatrist, psychologist, available for consult | Care manager, PHQ9 clinical | Yes, 12 months | Yes
RESPECT-D ^96,^ ^120^ | No | No | Care manager | By referral | Psychiatrist, available for consult, liaison between referral care and PCP | Care manager, PHQ9 clinical, medication adherence | Yes, 12 month continuation phase, then maintenance | No
Simon, 2004 ^84^ | No | No | Patient workbook (adapted from CBT in Treatment 2) | Treatment 1: By referral | Psychiatrist, psychologist available for consult | Limited, care manager, clinical, medication adherence | Yes, 20 weeks | No
No | No | Therapist | Treatment 2: 8 30–40 minute CBT sessions | Mental health clinician, provide CBT and care management | Care manager, clinical and adherence | Yes, 20 weeks | No
Adler, 2004 ^106,^ ^178^ | PC-SAD | Pharmacist | No | No | Psychiatrist, available for consult | Pharmacist, MADRS clinical, medication adherence | Yes, 18 months | No
Finley, 2003 ^108^ | No | Pharmacist care manager | No | No | Psychiatrist, available for consult | Pharmacist care manager, clinical and medication adherence | Yes, 6 months | No
Swindle, 2003 ^85^ | 2 item PRIME-MD | No | No | Warm hand off referral | Mental health clinical nurse specialist as care manager; psychiatrist, available for consult | Limited, care manager, clinical medication | Yes, 2 months | Yes
Partners in Care ^86,^ ^122,^ ^123,^ ^136,^ ^176^ | CIDI | Care manager | No | QI Med: By referral | Psychiatrist, available for consult | Care manager, clinical, medication adherence | Yes, randomized to 6 or 12 months | Yes
No | QI Therapy: 12 to 16 sessions CBT or 2 session brief CBT | Therapist, provide CBT; psychiatrist, available for consult | Therapy adherence. Unclear if clinical monitoring | No | Unclear
Datto, 2003 ^97^ | No | Patient and care manager | Limited, care manager | By referral | Psychiatrist, available for consult | Care manager, CESD clinical, medication adherence | Yes, 16 weeks | No
Hedrick, 2003 ^87^ | 4 methods | Patient | Patient | 6 session CBT | Social worker or clinical psychologist, provide CBT; psychiatrist, available for consult | Care manager, CESD clinical, medication adherence | Yes, 9 months | Yes
Katon, 1995 ^102^ | No | Patient, psychiatrist | No | By referral | Psychiatrist, provide direct patient care, consulted with PCP | Psychiatrist, medication adherence | Yes, up to 9 months | No
Katon, 1999 ^103^ | No | Patient, psychiatrist | No | By referral | Psychiatrist, provide direct patient care, consulted with PCP | Psychiatrist, medication adherence | Yes, up to 6 months | No
Katon, 1996 ^88^ | No | Patient, psychologist | Psychologist | Manualized brief CBT and adherence counseling, completed in 4 to 6 sessions | Psychologist, provide 4 to 6 sessions, clinical monitoring. Psychiatrist review medications. | Psychologist and psychiatrist, clinical and medication adherence | Yes, up to 6 months | No
Katon, 2001 ^98,^ ^115^ | No | Patient | Patient and care manager collaboration, devised during 2 face-to-face meetings | By referral | Psychiatrist, available for consult | Care manager, BDI clinical, results mailed to patients, patient care plan and medication | Yes, up to 3 months | No
Boudreau, 2002 ^104,^ ^175^ | No | No | No | By referral | Psychiatrist, available for consult | Pharmacist, PRIME-MD clinical, medication adherence | Yes, 12 months | Yes
Tutty, 2000 ^89^ | No | Patient | Therapist | 6 weekly 30 minute CBT | Psychotherapist, provided CBT | Therapist, medication adherence | No | No
Hunkeler, 2000 ^110^ | No | No | No | 10 6-minute calls by telehealth nurse for emotional support and behavioral interventions for medication adherence | Supervising clinical psychologist | Telehealth nurse, medication adherence | Yes, 16 weeks | No
QuEST ^5,^ ^111,^ ^124^ | 2 stage screener | Patient | No | By referral | Psychiatrist, available for consult | Primary care clinic nurse, clinical and adherence | Yes, 8 weeks | Yes
Simon, 2000 ^99^ Feedback and care management | No | No | No | By referral | Psychiatrist, available for consult | Medication adherence | Yes, 16 weeks | No
Hilty, 2007 ^105^ | No | Yes | No | Telepsychiatry visits (50 minutes at first, 20 minutes thereafter) offered at 2, 6, 10, 14, and 18 weeks | Telepsychiatrist, direct patient care and also consultation and training | Clinical, medication, and therapy adherence | Yes, 18 weeks | Not reported
Katzelnick, 2000 ^100^ | SCID | Patient | No | By referral | Psychiatrist, available for consult | Clinical and medication adherence | Yes, 42 weeks | No
Asarnow, 2005 ^114^ | CES-D, brief CIDI questionnaire | Care manager | Care manager | Up to 14 50-minute sessions of manualized CBT | Psychotherapist care manager, provide CBT and care management | Care manager, clinical, medication adherence | Yes, 6 months | Yes, based on Texas Algorithm Study
Anxiety Disorders
Rollman, 2005 ^101,^ ^177^ | Items from PRIME-MD | Care manager | Patient, workbook with care manager followup | Assisted referral | Psychiatrist, available for consult | Care manager, clinical and adherence | Yes, 12 months | Yes
CCAP ^9,^ ^90^ | 2 item screen | Patient and care manager | Patient and care manager | 6 CBT sessions in 3 months | Behavioral health specialist, provide CBT and care management | Care manager, clinical and adherence | Yes, 9 months | Yes
Roy-Byrne, 2001 ^109^ | 2 item screen | Patient | No | By referral | Psychiatrist, provide direct patient care, consulted with PCP | Psychiatrist, medication adherence | Yes, 12 months | No
Price, 2000 ^91^ | Shedler Quick Psycho Diagnostics Panel | Psychologist | Psychologist | CBT, not manualized. Goal of 4–6 sessions. | Psychologist, provide direct patient care, consulting psychiatrist | Psychologist, treatment adherence | No | Yes
Other Disorders
Katon, 1992 ^107^ | No | No | No | By referral | Psychiatrist, provided direct patient care, available for consult | No | No | No
Epstein, 2007 ^112^ | No | No | No | No | Psychiatrist, interpret behavioral scoring and provide titration recommendations | Researchers | Yes, 12 months | No

Patient collaboration features aim to improve a patient's engagement in the care process and support self-care. Reporting of program elements of patient education regarding the diagnosed mental illness and training in self-management skills was frequently limited. Even so, the large majority of studies reported providing patient education. ^69,^ ^83,^ ^86^ – ^95,^ ^97,^ ^98,^ ^100^ – ^103,^ ^105,^ ^106,^ ^108,^ ^109,^ ^111^ Ten studies provided printed or video materials to patients for self-study, ^84,^ ^87^ ^88,^ ^89,^ ^98,^ ^100,^ ^102,^ ^103,^ ^109,^ ^111^ while 13 studies involved a care manager or mental health therapist in the education process. ^83,^ ^86,^ ^90^ – ^95,^ ^97,^ ^101,^ ^106,^ ^108,^ ^113^ Training patients in self-management skills was less common. ^83,^ ^84,^ ^87^ – ^98,^ ^101,^ ^113^ Of those studies, only one study intervention arm relied solely on the patient to complete a self-help workbook on self-management skills without supervision by a care manager or therapist. ^84^ Studies of integrated care programs for anxiety disorders were more likely to use patient education and skill development, perhaps reflecting anxiety programs adapting what was learned from depression programs.

The Agency for Healthcare Research and Policy (AHRQ) guidelines for depression care included recommendations for evidence-based forms of psychotherapy. However, psychotherapy is a relatively new service for the primary care setting. About one-third of the studies used therapists or care managers to provide psychotherapy; ^69,^ ^83,^ ^84,^ ^86^ – ^88,^ ^90,^ ^91,^ ^93^ – ^95,^ ^105^ referral to specialty mental health services was more commonly used. ^84^ – ^86,^ ^92,^ ^96^ – ^104,^ ^107,^ ^109,^ ^111^ Cognitive behavioral therapy (CBT) was the most frequent form, ^83,^ ^84,^ ^86^ – ^91^ with problem solving therapy (PST) specifically used in three studies, ^93,^ ^94^ ^69^ and one study reporting using interpersonal therapy (IPT). ^95^ One study relied only on the potentially therapeutic relationship, with a telehealth nurse providing emotional support but not counseling. ^110^

Systematic followup was a strong component of the integrated care models, with 23 studies clearly reporting monitoring clinical outcomes of patients ^69,^ ^83^ – ^88,^ ^90,^ ^92^ – ^98,^ ^100,^ ^101,^ ^104^ – ^106,^ ^108,^ ^111,^ ^114^ and 29 studies monitoring patient adherence. ^83^ – ^106,^ ^108^ – ^111,^ ^114^ The studies that did not utilize systematic patient monitoring were early investigations of integrated care. ^107^ Monitoring and followup of patients were generally performed by care managers or therapists. Twenty-eight studies used formal followup protocols, ^69,^ ^83^ – ^88,^ ^90,^ ^92^ – ^106,^ ^108^ – ^112^ with eight studies following patients during the acute phase of treatment ^84,^ ^85,^ ^97^ – ^99,^ ^105,^ ^110,^ ^111^ and 20 studies with longer term followup into a continuation or maintenance phase. ^69,^ ^83,^ ^86^ – ^88,^ ^90,^ ^92^ – ^96,^ ^100^ – ^104,^ ^106,^ ^108,^ ^109,^ ^112^ Formal stepped care processes for patients not responding to treatment were used in 14 studies. ^69,^ ^83,^ ^85^ – ^87,^ ^90^ – ^95,^ ^101,^ ^104,^ ^111^

One study worthy of mention is a depression relapse prevention program that provided feedback of clinical outcomes to the patients themselves. This feedback to patients was unique among the integrated care programs. Ludman et al. described using bar charts as visual feedback aids for patients who were constructing written self-management plans. ^115^

Care management. Care management is a function, not a role. Care management is defined as “a collaborative process of assessment, planning, facilitation, and advocacy for options and services to meet an individual's health needs through communication and available resources to promote quality cost-effective outcomes.” ^116^ Many integrated models used designated care managers for the care management function and applied a limited, disease-focused approach. Table 7 describes the training and experience of care managers and how the care management function was performed.

Table 7 Description of care management

Outcome Project Name or Author | Title Certificate Training | New Staff | Role/Responsibilities* | Mode | Contact Frequency | Supervision
Depression Disorders
Fortney, 2006 ^92,^ ^131^ | Depression nurse care manager, RN, training or behavioral health experience not reported | Yes | Coordinate care, provide medical care | Telephone, interactive video website | Bi-weekly in acute phase, otherwise monthly for-up to 12 months through watchful waiting or continuance phase | Yes, psychiatrist
Grypma, 2006 ^93^ | Depression care manager (IMPACT post-study. Medical assistant hired to help DCM with patient tracking) | Yes | Coordinate care; provide medical care; provide behavioral health care, including relapse prevention plan. | Face-to-face, telephone | Based on patient's self-determined need | Psychiatrist consultation as needed
IMPACT ^2,^ ^130^ ^94,^ ^121,^ ^173^ | Depression care specialist, nurse or psychologist, training in behavioral care for study. | Yes | Coordinate care; provide medical care; provide behavioral health care, including relapse prevention plan. | Face-to-face, telephone | Bi-weekly in acute phase, otherwise monthly for up to 12 months | Yes, psychiatrist
Clarke, 2005 ^83^ | No title, duties performed by master's level mental health specialist | Yes | Provide medical care; provide behavioral health care | Face-to-face, telephone | Up to 9 sessions during 3 month acute phase, 6 contacts over 9 month continuation phase | Yes, study psychiatrist
PROSPECT ^95,^ ^125,^ ^135^ | Depression care managers, nurse, social worker, clinical psychologist | Yes | Coordinate care, provide medical care, provide behavioral health care | Face-to-face, telephone | Unclear | Not reported
Pathways ^69,^ ^113^ | Depression care specialist, RN, trained for study | Yes | Coordinate care, provide medical care, provide behavioral health care | Face-to-face, telephone, mail | Bi-weekly for acute phase, monthly thereafter for up to 12 months | Yes, psychiatrist
RESPECT-D ^96,^ ^120^ | Care manager, no special training, during trial; most were primary care or mental health nursing | No | Coordinate care, provide medical care | Telephone | Minimum of monthly for acute phase, bi-monthly for continuation phase, every 6–12 months for maintenance. | Yes, psychiatrist
Simon, 2004 ^84^ | Care manager, mental health clinicians with at least 1 year of depression assessment experience | Yes | Coordinate care Treatment 1: Provide medical care Treatment 2: Provide medical care, provide behavioral health care | Telephone, mail | 3 telephone contacts within 12 weeks, 1 mail contact at 20 weeks. | Yes, psychiatrist
Adler, 2004 ^106,^ ^178^ | No title, duties performed by pharmacist | No | Coordinate care, provide medical care | Face-to-face, telephone | At least 9 contacts over 18 months. | Yes, psychiatrist
Finley, 2003 ^108^ | Care manager, clinical pharmacist | Yes | Provide medical care | Face-to-face, telephone | 4 contacts during medication trial, 3 followups over remainder of 6 months | Yes, psychiatrist
Swindle, 2003 ^85^ | Clinical nurse specialist, mental health service experience | No (transfer of staff) | Coordinate care, provide medical care | Face-to-face, telephone | Contact at 2 weeks, 1 month, and 2 months following initial visit. | Yes, psychiatrist
Partners in Care ^86,^ ^122,^ ^123,^ ^136,^ ^176^ | QI - Med: Depression nurse specialist, local practice nurse trained for study | Yes | Provide medical care | Face-to-face | Weeks 2, 4, and monthly thereafter, randomized to 6 or 12 month followup | Yes, psychiatrist
QI - Therapy: Depression nurse specialist in limited capacity | No | Patient assessment and education | Face-to-face | No | Yes, psychiatrist
Datto, 2003 ^97^ | Disease management nurse, extra training and experience in mental health | Yes | Coordinate care, provide medical care | Telephone | Interval monitoring for 16 week acute phase | Yes, psychiatrist
Hedrick, 2003 ^87^ | No title, social work staff | Yes | Coordinate care, provide medical care | Telephone | Regular schedule for 9 months | Yes, psychiatrist
Katon, 1995 ^102^ | No care manager | NA | Psychiatrist reviewed records for adherence | Face-to-face | 2 to 4 visits in acute phase | NA
Katon, 1999 ^103^ | No care manager | NA | Psychiatrist reviewed records for adherence | Face-to-face, telephone | 2 to 4 visits in acute phase, 1 to 2 telephone followup contacts between visits | NA
Katon, 1996 ^88^ | No care manager | NA | Psychologist collected medication and clinical monitoring | Face-to-face, telephone | 4 to 6 visits in first 6 weeks, 4 telephone contacts at 8, 12, 18, and 30 weeks | NA
Katon, 2001 ^98,^ ^115^ | Depression specialist, psychologist, nurse practitioner, and social worker with advanced degrees | Yes | Coordinate care, provide medical care, provide behavioral care | Face-to-face, telephone, mail | 2 face-to-face, 3 telephone contacts mixed with 4 mailed personalized feedback letters over 12 months | Yes, psychiatrist
Boudreau, 2002 ^104,^ ^175^ | No title, duties performed by pharmacist | Yes | Provide medical care | Face-to-face, telephone | Weekly for 4 weeks, biweekly for 2 months, then bimonthly until 12 months | Yes, psychiatrist
Tutty, 2000 ^89^ | No care manager | NA | Therapist may prompt PCP based on computer report of clinical monitoring and medication adherence | Telephone | 6 telephone sessions over 6 weeks | NA
Hunkeler, 2000 ^110^ | No care manager | No | Primary care nurses offered emotional and instrumental support, medication adherence | Telephone | 12 to 14 calls during 16 weeks of acute phase | Yes, clinical psychologist
QuEST ^5,^ ^111,^ ^124^ | No care manager | No | Clinical monitoring and medication adherence by clinic nurse | Face-to-face, telephone | 6 contacts over 6 weeks, with option to extend for 2 weeks | Yes, PCP
Simon, 2000 ^99^ arm 2 Feedback and care management | Care manager, no behavioral health experience | Yes | Coordination of care | Telephone | A minimum of 3 10–15 minute telephone contacts, weeks 1, 8 and 16 | Yes, psychiatrist (case load approximately 100 patients)
Hilty, 2007 ^105^ | Telemedicine coordinator, training not reported | Yes | Coordination of care, provide medical care | Telephone | Not reported | Not reported
Katzelnick, 2000 ^100^ | Coordinator, clinical mental health experience | Yes | Coordination of care, provide medical care | Telephone | 2 to 5 contacts over 42 weeks (PCP visits at weeks 1, 3, 6, and 10, then every 10 weeks) | No
Asarnow, 2005 ^114^ | Care manager, master's or doctorate in mental health or nursing | Yes | Coordinate care, provide medical care, provide behavioral health care | Face-to-face, telephone | Variable by site as determined by quality improvement team | Not reported
Anxiety Disorders
Rollman, 2005 ^101,^ ^177^ | Care manager, no special behavioral training beyond training for study | Yes | Coordinate care; provide medical care | Telephone | Every 1–3 months in continuation phase for up to 12 months | Yes, team of psychiatrist, psychologist, internist, family practitioner
CCAP ^9,^ ^90^ | Behavioral health specialist, master or new doctoral levels with no or minimal CBT, trained for study | Yes | Coordinate care, provide medical care, provide behavioral health care | Face-to-face, telephone | 6 session during 3 month acute phase, 6 contacts over 9 month continuation phase | Yes, psychiatrist
Roy-Byrne, 2001 ^109^ | No care manager | NA | Psychiatrist provided medication and followup care | Face-to-face, telephone | 2 visits and 2 telephone contacts in acute stage, through 8 weeks, 5 contacts in 10 month continuation phase | NA
Price, 2000 ^91^ | No care manager | NA | Coordination of care clinical, medication, and treatment monitoring performed by psychologist | Face-to-face | Goal of 4 to 6 sessions | NA
Other Disorders
Katon, 1992 ^107^ | No care manager | NA | None | NA | Not reported | NA
Epstein, 2007 ^112^ | No care manager | NA | Monitor medication maintenance carried out by consultation service and reported to PCP | NA | NA | NA

* Role/Responsibilities: Coordinate care is noted when the care manager coordinates care for the patient, including follow up if patients miss appointments. Provide medical care is noted when the care managers monitor medication adherence, side effects, etc. Provide behavioral health care is noted when the care manager providing brief psychotherapeutic treatments, etc.

For 19 studies, the care manager was a new position in the practice. ^69,^ ^83,^ ^84,^ ^86,^ ^87,^ ^90,^ ^92^ – ^95,^ ^97^ – ^101,^ ^104,^ ^105,^ ^108,^ ^114^ Training and prior experience for these care managers ranged from bachelor level employees with some clinic staff experience or nurses with no prior mental health experience to master's or doctoral level mental health providers. Of note were two studies that used clinical pharmacists to deliver care management. ^106,^ ^108^ Virtually all care managers were supervised by psychiatrists.

Delivery of care management was most commonly accomplished by face-to-face meetings with patients ^69,^ ^83,^ ^85,^ ^86,^ ^88,^ ^90,^ ^91,^ ^93^ – ^95,^ ^98,^ ^102^ – ^104,^ ^106,^ ^108,^ ^109,^ ^111^ and/or telephone contact. ^69,^ ^83^ – ^88,^ ^90,^ ^92^ – ^101,^ ^103^ – ^106,^ ^108^ – ^111^ There was a wide range of frequency of contacts. Protocols for contacts may call for a minimum of two to three contacts in the acute phase for care managers who do not provide some form of psychotherapy, to six or more sessions for care managers who do. Monthly contact with patients was typical for the continuation phase of protocols.

There was a marked difference in the use of care management for the disorders represented by the studies. Somatizing and other disorders were far less likely to use care management in the integration models.

Of those illnesses that routinely used care managers in integrated care, there were no major discernible differences in models applied to different mental health illnesses, except for one noteworthy study. The Katon et al., 2001 study ^98^ focused on relapse prevention for depression patients, many of whom had already participated in a collaborative care model. As reported by Ludman et al., ^115^ the care managers, known as depression specialists, provided support and counseling to patients and guided them through a process to develop self-care prevention plans. Patients received graphical representations of their depression severity scores over time. By linking the severity score feedback with the prevention plan created by the patient, the patient might learn to recognize triggers and presyndromal signs of possible impending relapses.

Theoretical support for models. Wagner's CCM ^46^ is the conceptual model most often identified as informing the intervention; nine of the studies explicitly mentioned the model of integration was based on at least some elements of the CCM ^86,^ ^87,^ ^92,^ ^94,^ ^96,^ ^98,^ ^99,^ ^101,^ ^111^ and some of the reviews in the area frame the study of integration within the CCM. ^71,^ ^78^ For the most part, however, the interventions fall well short of fully implementing all the key elements of the CCM. Wagner ^46^ suggested that practice re-design, patient education, an enhanced expert system (providing education and decision support to clinicians) and a developed information system that could track outcomes and provide feedback to providers are essential to providing high quality chronic care. All should also be implemented in an environment characterized by the use of evidence-based care. These recommendations are quite broad, and to some degree one can argue that each integration intervention addresses at least part of the CCM. But, the models of integration often fail to explicate how (and why) they operationalize the CCM in specific ways for the treatment of mental illness within the primary care settings or how the specific elements of the interventions are linked to the process of care.

While the conceptual models underlying studies of integration are not well developed, all of the studies at least implicitly argue that integration is needed to address specific problems in the process of care that lead to poor clinical and quality of life outcomes. Figure 1 in Chapter 1 shows the elements of the care process that are generally targeted by integration efforts because they are assumed to be associated with improved clinical and quality of life outcomes.

First, identification of patients with mental health problems in primary care has long been recognized as inadequate. For example, studies show that primary care fails to recognize between one-third and one-half of depression cases. ^57,^ ^117^ A substantial body of evidence, however, indicates that improving case identification alone is not sufficient for improving outcomes for patients; ^57^ systematic therapeutic action is required. Thus integration efforts do not simply target case-identification.

Second, integration proponents recognize that provider practices often lead to inadequate care. The separation of mental and physical health into different medical specialties encourages providers to focus on only the conditions that fit within their specialty. Primary care physicians are often uncomfortable addressing mental health issues. Moreover, when primary care physicians do provide treatment for mental health problems, it often falls below standards for quality care. ^35,^ ^36^ Greater structure through guidelines may help to address this problem.

Effect of levels of integration on outcomes: Provider integration. Forest plots of symptom severity, response rates, and remission rates were created for the three forms of integration described above: provider integration, integrated process of care, and matrix integration. These plots examine essentially the same pool of studies, which are regrouped to reflect their meeting various taxonomic approaches to integration. Because of high levels of heterogeneity, it was not possible to pool studies to estimate mean effects. Improvements in symptom severity are plotted to the left of the nonsignificance line as reductions in scores are better. Improvements in treatment response and remission rates are plotted to the right of the nonsignificance line. If increased levels of provider integration improve outcomes, one would expect to see a drift from greater to lesser improvements as the level of integration declines.

Figures 4–6 are forest plots for symptom severity, response rates, and remission rates, respectively, for unpooled depression trials sorted by provider integration levels. The large majority of trials (N=22) had lower levels of provider integration. Also noted is that trials in the higher integration levels tend to be older. There is no discernable effect of provider integration level on outcomes based on this data. Of the plotted data, only the IMPACT trial shows consistent improvement in symptom severity. Significant improvements in treatment response and remission rates are consistent across the integration levels. Looking at the full set of trials listed in Table 8, which groups all trial outcomes by integration level and mental health illness category, it does not appear that the exclusions biased the results. The limited numbers of anxiety trials exhibit a similar pattern. The results would not differ if the two low quality trials were not included in the analysis. ^85,^ ^105^ The pattern of results is also not affected by comparison group.

Table 8 Clinical outcomes by level of provider integration

Outcome Project or Author | Measurement | Patient Category | Assessment Period | Direction of Effect | Result/Effect Size | Comment
MENTAL ILLNESS SYMPTOMS (SEVERITY)
High Level (Depression)
Katon, 1999 and 2002 ^3,^ ^103^ | SCL-20 | All patients | 3 months | Intervention | P=.003
Katon, 1999 and 2002 ^3,^ ^103^ | SCL-20 | 6 months | Intervention | P=.04 | Treatment × time
Katon, 1999 and 2002 ^3,^ ^103^ | SCL-20 | All patients | 28 months | Intervention | P=.05 | Treatment × time
Katon, 1999 and 2002 ^3,^ ^103^ | SCL-20 | Moderate severity | 28 months | Intervention | P=.004 | Treatment × time
High severity | 28 months | | NS
Lin, 1999 ^4^ (followup of Katon, 1995 and Katon, 1996) | SCL-20 | | 19 months | | NS
Inventory for depressive symptomatology | | 19 months | | NS
Hedrick, 2003 ^87^ | SCL-20 | | 3 months | Intervention | -0.17, 95% CI 0.31; -0.03, p<.05 | Equalized amount of treatment between collaborative and consult-liaison models; attention control
9 months | | NS
Swindle, 2003 ^85^ | Beck depression inventory | All patients | 3 months | | NS | No difference in outcomes for major depression or dysthymia. Several CNS were not voluntary, did not follow protocol, etc.
Swindle, 2003 ^85^ | Beck depression inventory | 12 months | | NS | | No difference in outcomes for major depression or dysthymia. Several CNS were not voluntary, did not follow protocol, etc.
Swindle, 2003 ^85^ | Beck depression inventory | Major depression | 3 months | | NS | No difference in outcomes for major depression or dysthymia. Several CNS were not voluntary, did not follow protocol, etc.
12 months | | NS
High Level (Anxiety)
Price, 2000 ^91^ | Shedler Quick Psycho Diagnostics Panel (Anxiety) | | 6 months | Intervention | P=.046
High Level (Other Disorders)
Katon, 1992 ^107^ | SCL somatization | | 6 months | | NS
Katon, 1992 ^107^ | 12 months | | NS
Katon, 1992 ^107^ | SCL depression | | 6 months | | NS
Katon, 1992 ^107^ | 12 months | | NS
Katon, 1992 ^107^ | SCL anxiety | | 6 months | | NS
12 months | | NS
Intermediate I Level (Depression)
IMPACT ^2,^ ^179^ | SCL-20 | | 3 months | Intervention | -0.28, 95% CI 0.34; -0.21, p<.001
IMPACT ^2,^ ^179^ | SCL-20 | | 6 months | Intervention | -0.28, 95% CI 0.35; -0.19, p<.001
IMPACT ^2,^ ^179^ | SCL-20 | | 12 months | Intervention | NNT=4
IMPACT ^2,^ ^179^ | SCL-20 | | 18 months | Intervention | NNT=6
24 months | Intervention | NNT=9
Grypma, 2006 ^93^ | PHQ-9 score | All depression patients | 6 months | | NS | IMPACT intervention group compared to post-study integrated care group. Same results for less resources
Patients over 60 years | 6 months | | NS
PROSPECT ^125^ | Hamilton Depression Rating Scale | All patients | 4 months | | -3.5, 95% CI -4.7; -2.4, p<.001
PROSPECT ^125^ | Hamilton Depression Rating Scale | All patients | 8 months | | -2.1, 95% CI -3.4; -0.9, p<.001
PROSPECT ^125^ | Hamilton Depression Rating Scale | 12 months | | -1.8, 95% CI -3.1; -0.5, p=.006
PROSPECT ^125^ | Hamilton Depression Rating Scale | Major depression | 4 months | | -4.6, 95% CI -6.2; -3.1, p<.001
PROSPECT ^125^ | Hamilton Depression Rating Scale | Major depression | 8 months | | -2.5, 95% CI -4.1; -0.9, p.003
PROSPECT ^125^ | Hamilton Depression Rating Scale | 12 months | | -2.1, 95% CI -3.7; -0.4, p=.02
PROSPECT ^125^ | Hamilton Depression Rating Scale | Clinically significant minor depression | 4 months | | NS
PROSPECT ^125^ | Hamilton Depression Rating Scale | Clinically significant minor depression | 8 months | | NS
12 months | | NS
Katon, 2001 ^98^ | SCL-20 | | 12 months | | NS
Intermediate I Level (Anxiety)
Roy-Byrne, 2001 ^109^ | PDSS Panic disorder severity scale | | 3 months | | NS | Intervention × time p=.05, driven by reduction in anticipatory anxiety
Roy-Byrne, 2001 ^109^ | PDSS Panic disorder severity scale | | 6 months | Intervention | P=.003 | Intervention × time p=.05, driven by reduction in anticipatory anxiety
Roy-Byrne, 2001 ^109^ | PDSS Panic disorder severity scale | | 9 months | | NS | Intervention × time p=.05, driven by reduction in anticipatory anxiety
Roy-Byrne, 2001 ^109^ | 12 months | | NS
Roy-Byrne, 2001 ^109^ | Anxiety sensitivity scale | | 3 months | Intervention | P=.002 | Intervention × time p=.018
Roy-Byrne, 2001 ^109^ | Anxiety sensitivity scale | | 6 months | Intervention | P<.001 | Intervention × time p=.018
Roy-Byrne, 2001 ^109^ | Anxiety sensitivity scale | | 9 months | | NS | Intervention × time p=.018
Roy-Byrne, 2001 ^109^ | 12 months | Intervention | P=.035
Roy-Byrne, 2001 ^109^ | Panic related agoraphobic avoidance | | 12 months | | NS
Roy-Byrne, 2001 ^109^ | Fear Questionnaire agoraphobic subscale | | 12 months | | NS
Roy-Byrne, 2001 ^109^ | CES-D | | 3 months | Intervention | P=.002 | Intervention × time p=.03
Roy-Byrne, 2001 ^109^ | CES-D | | 6 months | Intervention | P=.005
Roy-Byrne, 2001 ^109^ | CES-D | | 9 months | Intervention | P=.036
12 months | Intervention | P=.02
Intermediate II Level (Depression)
Clarke, 2005 ^83^ | CES-D | | 12 months | | NS | Study may have been under-powered to compare 2 active treatments. About 75% remission in both groups within 3 months.
Clarke, 2005 ^83^ | Hamilton Depression Rating Scale | | 12 months | | NS | Study may have been under-powered to compare 2 active treatments. About 75% remission in both groups within 3 months.
Youth Self Report | | 12 months | | NS
Simon, 2004 ^84^ | SCL-20 | Telephone psycho-therapy plus care management | 6 months | Intervention | P<.001 | Difference between groups is equal to ½ of the SD of scores in general population
Telephone care management | 6 months | Intervention | NS
Boudreau, 2002 ^175^ | SCL-20 | | 12 months | | NS
Finley, 2003 ^108^ | Brief inventory for depressive symptoms | | 6 months | | NS
Partners in Care ^122,^ ^123^ | Percent with probable depression based on CIDI screen | All interventions | 6 months | Any intervention | P=.001
Partners in Care ^122,^ ^123^ | Percent with probable depression based on CIDI screen | 12 months | Any intervention | P=.005
Partners in Care ^122,^ ^123^ | Percent with probable depression based on CIDI screen | QI-Therapy | 6 months | Intervention | P<.05
Partners in Care ^122,^ ^123^ | Percent with probable depression based on CIDI screen | QI-Therapy | 12 months | Intervention | P<.05
Partners in Care ^122,^ ^123^ | Percent with probable depression based on CIDI screen | QI-Therapy | 18 months | | NS
Partners in Care ^122,^ ^123^ | 24 months | | NS
Partners in Care ^122,^ ^123^
Partners in Care ^122,^ ^123^ | Overall poor outcome: patient scored depressed if score in depressed range of all 3 CIDI screen, full 12-month CIDI, and CES-D, vs. 2 or fewer measures. | QI-Therapy | 6 months | Intervention | P<.05
Partners in Care ^122,^ ^123^ | Overall poor outcome: patient scored depressed if score in depressed range of all 3 CIDI screen, full 12-month CIDI, and CES-D, vs. 2 or fewer measures. | QI-Therapy | 12 months | Intervention | P<.05
18 months | Overall poor outcome: patient scored depressed if score in depressed range of all 3 CIDI screen, full 12-month CIDI, and CES-D, vs. 2 or fewer measures. | QI-Therapy | Intervention, usual care and QI-Meds | P<.05
24 months | Intervention, QI-Meds | P<.05
Asarnow, 2005 ^114^ | CES-D | | 6 months | Intervention | -2.9, 95% CI -5.3; -0.4, p=.02
Percent with CES-D in severe range ≥ 24 | | 6 months | Intervention | OR 0.6, 95% CI 0.4, 0.9, p=.02
Intermediate II Level (Anxiety)
CCAP ^9^ | Anxiety sensitivity index score | | 3 months | Intervention | Effect size 0.44
CCAP ^9^ | Anxiety sensitivity index score | | 6 months | Intervention | Effect size 0.45
CCAP ^9^ | Anxiety sensitivity index score | | 9 months | Intervention | Effect size 0.44
CCAP ^9^ | 12 months | Intervention | Effect size 0.43
CCAP ^9^ | CES-D | | 3 months | Intervention | Effect size 0.29
CCAP ^9^ | CES-D | | 6 months | Intervention | Effect size 0.29
CCAP ^9^ | CES-D | | 9 months | Intervention | Effect size 0.27
12 months | Intervention | Effect size 0.26
Intermediate II Level (Other Disorders)
Epstein, 2007 ^112^ | Conners Parent Rating Scale | | 12 months | | NS
Low Level (Depression)
Tutty, 2000 ^89^ | SCL-20 | | 3 months | Intervention | P=.03
6 months | Intervention | P=.03
Hunkeler, 2000 ^110^ (reporting telehealth nurse only, not peer support) | Hamilton depression rating score | | 6 weeks | | NS
Hunkeler, 2000 ^110^ (reporting telehealth nurse only, not peer support) | 6 months | Intervention | P=.006
Hunkeler, 2000 ^110^ (reporting telehealth nurse only, not peer support) | Beck depression rating score | | 6 weeks | | NS
6 months | | NS
RESPECT-D ^120^ | SCL-20 | | 3 months | Intervention | -0.16, 95% CI -0.32; -0.002, p=.048
6 months | Intervention | -0.20, 95% CI -0.39 -0.014, p=.036
Adler, 2004 ^106^ | Modified Beck depression inventory | | 3 months | | NS
6 months | | NS
Partners in Care ^122,^ ^123^ | Percent with probable depression based on CIDI screen | QI-Meds | 6 months | Intervention | P<.05 | Time trends: Percent of usual care with probable depression dropped from 6 to 24 months while QI-Meds climbed. QI-Therapy remained relatively flat. QI-Meds significantly higher than QI-Therapy at 24 months.
Partners in Care ^122,^ ^123^ | Percent with probable depression based on CIDI screen | QI-Meds | 12 months | Intervention | P<.05
Partners in Care ^122,^ ^123^ | Percent with probable depression based on CIDI screen | QI-Meds | 18 months | | NS
Partners in Care ^122,^ ^123^ | 24 months | | NS
Partners in Care ^122,^ ^123^ | Overall poor outcome: patient scored depressed if score in depressed range of all 3 CIDI screen, full 12-month CIDI, and CES-D, vs. 2 or fewer measures. | QI-Meds | 6 months | | NS
Partners in Care ^122,^ ^123^ | Overall poor outcome: patient scored depressed if score in depressed range of all 3 CIDI screen, full 12-month CIDI, and CES-D, vs. 2 or fewer measures. | QI-Meds | 12 months | | NS
Partners in Care ^122,^ ^123^ | Overall poor outcome: patient scored depressed if score in depressed range of all 3 CIDI screen, full 12-month CIDI, and CES-D, vs. 2 or fewer measures. | QI-Meds | 18 months | | NS
24 months | | NS
QuEST ^124^ | Modified CES-D | Patients beginning new treatment episode | 6 months | Intervention | Effect size = 0.43
QuEST ^124^ | Modified CES-D | Patients recently treated | 6 months | | NS
Patients beginning new treatment episode, who find antidepressants acceptable | 6 months | Intervention | Effect size = 0.83 | This patient group also showed improvement in physical functioning, SF12 PCS, and satisfaction with care
Simon, 2000 ^99^ | SCL-20 | Care management arm | 6 months | Intervention | P=.008
Katzelnick, 2000 ^100^ | Hamilton depression score | | 3 months | Intervention | P=.04 | Significant group × time as well
Katzelnick, 2000 ^100^ | Hamilton depression score | | 6 months | Intervention | P<.001 | Significant group × time as well
12 months | Intervention | P=.005
Low Level (Anxiety)
Rollman, 2005 ^101^ | PDSS Panic Disorder Severity Scale | All patients | 12 months | Intervention | 0.33, 95% CI 0.04; 0.62, p=.02 | Intervention × time
Rollman, 2005 ^101^ | Panic disorder | 12 months | Intervention | 0.57, 95% CI 0.18; 0.96, p=.003 | Intervention × time
Rollman, 2005 ^101^ | SIGH-A Hamilton anxiety rating scale | All patients | 12 months | Intervention | 0.38, 95% CI 0.09; 0.67, p=.03 | Intervention × time,
Rollman, 2005 ^101^ | General anxiety disorder | 12 months | | NS
Hamilton depression rating scale | All patients | 12 months | Intervention | 0.57, 95% CI 0.25; 0.46, p=.03 | Intervention × time
TREATMENT RESPONSE
High Level (Depression)
Hedrick, 2003 ^87^ | Percent with 50% improvement in SCL-20 | | 3 months | | NS
9 months | | NS
Intermediate I Level (Depression)
Grypma, 2006 ^93^ | Percent with 50% improvement in PHQ-9 | All depression patients | 6 months | | NS | IMPACT intervention group compared to post-study integrated care group
Patients over 60 years | 6 months | | NS
IMPACT ^2,^ ^179^ | Percent with 50% improvement in SCL-20 | | 3 months | Intervention | 2.73, 95% CI 2.10; 3.54, p<.001
IMPACT ^2,^ ^179^ | Percent with 50% improvement in SCL-20 | | 6 months | Intervention | 2.21, 95% CI 1.76; 2.76, p<.001
IMPACT ^2,^ ^179^ | Percent with 50% improvement in SCL-20 | | 12 months | Intervention | 26.85, 95% CI 22.34; 31.35, p<.0001
IMPACT ^2,^ ^179^ | Percent with 50% improvement in SCL-20 | | 18 months | Intervention | 16.99, 95% CI 12.34; 21.64, p<.0001
24 months | Intervention | 10.87, 95% CI 6.16; 15.57, p<.0001
Pathways ^113^ | Percent with 50% improvement in SCL-90 | | 6 months | | NS
12 months | | NS
Katon, 1996 ^88^ | Percent with 50% improvement in SCL-20 | Major depression | 4 months | Intervention | P=.002 | Group × time trend
Katon, 1996 ^88^ | Percent with 50% improvement in SCL-20 | 7 months | Intervention | P=.04 | Group × time trend
Katon, 1996 ^88^ | Percent with 50% improvement in SCL-20 | Minor depression | 4 months | | NS
7 months | | NS
Intermediate I Level (Anxiety)
Roy-Byrne, 2001 ^109^ | 40% reduction in PDSS | | 3 months | | NS
Roy-Byrne, 2001 ^109^ | 40% reduction in PDSS | | 6 months | Intervention | P=.001
Roy-Byrne, 2001 ^109^ | 40% reduction in PDSS | | 9 months | | NS
12 months | Intervention | P=.048
Intermediate II Level (Depression)
Simon, 2004 ^84^ | Percent with 50% improvement in SCL-20 | Telephone care management | 6 months | Intervention | NS | Usual care as comparison
Telephone psychotherapy plus care management | 6 months | Intervention | NNT=6.4 | Usual care as comparison
Finley, 2003 ^108^ | Percent with 50% improvement in brief inventory for depressive symptoms | | 6 months | | NS
Low Level (Depression)
Tutty, 2000 ^89^ | Percent with 50% improvement in SCL-20 | | 3 months | | NS
6 months | | NS
Hunkeler, 2000 ^110^ (reporting telehealth nurse only, not peer support) | Percent with 50% improvement in Hamilton depression rating score | | 6 weeks | Intervention | P=.01
6 months | Intervention | P=.003
Fortney, 2006 ^92^ | Percent with 50% improvement in SCL-20 | | 6 months | Intervention | NNT=11
12 months | Intervention | NS
PROSPECT ^125,^ ^127^ | Percent with 50% improvement in HRSD | All patients | 4 months | | OR 2.7, 95% CI 1.5; 4.9, p=.001 | At 8 months, patients taking medication only showed more improvement than patients with IPT only, P=.02
PROSPECT ^125,^ ^127^ | Percent with 50% improvement in HRSD | All patients | 8 months | | OR 2.1, 95% CI 1.1; 3.8, p=.02 | At 8 months, patients taking medication only showed more improvement than patients with IPT only, P=.02
PROSPECT ^125,^ ^127^ | Percent with 50% improvement in HRSD | 12 months | | OR 2.0, 95% CI 1.1; 3.8 P=.02
PROSPECT ^125,^ ^127^ | Percent with 50% improvement in HRSD | Major depression | 4 months | | OR 3.9, 95% CI 1.8; 8.5, p<.001
PROSPECT ^125,^ ^127^ | Percent with 50% improvement in HRSD | Major depression | 8 months | | OR 3.0, 95% CI 1.4; 6.4 P=.006
PROSPECT ^125,^ ^127^ | Percent with 50% improvement in HRSD | 12 months | | NS
PROSPECT ^125,^ ^127^ | Percent with 50% improvement in HRSD | Clinically significant minor depression | 4 months | | NS
PROSPECT ^125,^ ^127^ | Percent with 50% improvement in HRSD | Clinically significant minor depression | 8 months | | NS
12 months | | NS
RESPECT-D ^120^ | Percent with 50% improvement in SCL-20 | | 3 months | Intervention | OR 2.2, 95% CI 1.4; 3.4, p=.001
6 months | Intervention | OR 1.7, 95% CI 1.1; 2.7, p=.021
Datto, 2003 ^97^ | Percent with 50% improvement in CES-D | | 16 weeks | | NS
Datto, 2003 ^97^ | Percent with 50% improvement in Beck depression rating score | | 6 weeks | | NS
6 months | | P=.05
Simon, 2000 ^99^ | Percent with 50% improvement in SCL-20 | Care management arm | 6 months | Intervention | OR 2.22, 95% CI 1.31; 3.75
Katzelnick, 2000 ^100^ | Percent with 50% improvement in Hamilton depression score | | 12 months | Intervention | P<.001 | 53.2% compared to 32.8%
Low Level (Anxiety)
Rollman, 2005 ^101^ | 40% reduction in SIGH-A | All patients | 12 months | Intervention | 30.8, 95% CI 17.0; 44.7, p<.001
Rollman, 2005 ^101^ | General anxiety disorder | 12 months | | NS
Rollman, 2005 ^101^ | 40% reduction in PDSS | All patients | 12 months | Intervention | 20.7, 95% CI 9.7; 31.5, p<.001
Rollman, 2005 ^101^ | Panic disorder | 12 months | Intervention | 32.2, 95% CI 15.5; 48.9, p<.001
40% reduction in Hamilton depression rating | All patients | 12 months | Intervention | 28.5, CI 15 to 42.6, p<.001
REMISSION
High Level (Depression)
Katon, 1999 ^103^ | Percent with SCID ≤ 1 | | 3 months | Intervention | P=.01
6 months | Intervention | P=.05
Hedrick, 2003 ^87^ | Percent with SCL-20 ≥1.75 | | 3 months | | NS | Collaborative care patients with baseline scores above 1.75 were significantly less likely to be above 1.75 at 3 months.
High Level (Anxiety)
Roy-Byrne, 2001 ^109^ | Anxiety sensitivity score <20 | | 3 months | Intervention | P=.004
Roy-Byrne, 2001 ^109^ | Anxiety sensitivity score <20 | | 6 months | Intervention | P=.004
Roy-Byrne, 2001 ^109^ | Anxiety sensitivity score <20 | | 9 months | | NS
12 months | Intervention | P=.005
Intermediate I Level (Depression)
IMPACT ^2,^ ^121^ | Percent with SCL-20 <0.5 | | 3 months | Intervention | 3.63, 95% CI 2.46; 5.38, p<.001
IMPACT ^2,^ ^121^ | Percent with SCL-20 <0.5 | | 6 months | Intervention | 2.16, 95% CI 1.69; 2.76, p<.001
IMPACT ^2,^ ^121^ | Percent with SCL-20 <0.5 | | 12 months | Intervention | 17.48, 95% CI 13.78; 21.18, p<.0001
IMPACT ^2,^ ^121^ | Percent with SCL-20 <0.5 | | 18 months | Intervention | 9.31, 95% CI 5.77; 12.85, p<.0001
IMPACT ^2,^ ^121^ | 24 months | Intervention | 5.65, 95% CI 2.12; 9.17, p=.0018
Percent with SCID ≤1 | | 6 months | Intervention | OR 0.50, 95% CI 0.40; 0.62, P<.001
Intermediate I Level (Anxiety)
Price, 2000 ^91^ | Shedler quick diagnostics panel <10 (anxiety) | | 6 months | Intervention | P=.025 | 55.6% intervention vs. 22.8% control achieved remission
Intermediate II Level (Depression)
Boudreau, 2002 ^175^ | Percent with major depression as measured with SCID | | 12 months | | NS
Finley, 2003 ^108^ | Percent with brief inventory for depressive symptoms <9 | | 6 months | | NS
Intermediate II Level (Anxiety)
CCAP ^9^ | Anxiety sensitivity score <20 | | 3 months | Intervention | Effect size 0.40
CCAP ^9^ | Anxiety sensitivity score <20 | | 6 months | Intervention | Effect size 0.48
CCAP ^9^ | Anxiety sensitivity score <20 | | 9 months | Intervention | Effect size 0.47
CCAP ^9^ | 12 months | Intervention | Effect size 0.51
CCAP ^9^ | High end-state functioning | | 3 months | Intervention | Effect size 0.23
CCAP ^9^ | High end-state functioning | | 6 months | Intervention | Effect size 0.29
CCAP ^9^ | High end-state functioning | | 9 months | Intervention | Effect size 0.32
12 months | Intervention | Effect size 0.34
Low Level (Depression)
Tutty, 2000) ^89^ | Percent with SCID ≤1 | | 3 months | | NS
6 months | | NS
Partners in Care ^122^ | Percent with modified CES-D < 20 | | 6 months | All interventions | P=.005
Partners in Care ^122^ | 12 months | All interventions | P=.04
Percent without clinical diagnosis, based on full 12-month CIDI | | 2 years | QI-Therapy, vs. QI-Meds | P=.04
Fortney, 2006 ^92^ | Percent with SCL-20 <0.5 | | 6 months | Intervention | NS
12 months | Intervention | NNT=11
PROSPECT ^125,^ ^127^ | Percent with HRSD <10 | All patients | 4 months | | OR 3.7, 95% CI 1.7; 7.7, p=<.001 | Treatment × time p<.01 for medication only, vs. IPT only
PROSPECT ^125,^ ^127^ | Percent with HRSD <10 | All patients | 8 months | | NS | Treatment × time p<.01 for medication only, vs. IPT only
PROSPECT ^125,^ ^127^ | Percent with HRSD <10 | 12 months | | NS
PROSPECT ^125,^ ^127^ | Percent with HRSD <10 | Major depression | 4 months | | OR 6.7, 95% CI 2.5; 17.9, p<.001
PROSPECT ^125,^ ^127^ | Percent with HRSD <10 | Major depression | 8 months | | NS
PROSPECT ^125,^ ^127^ | Percent with HRSD <10 | 12 months | | NS
PROSPECT ^125,^ ^127^ | Percent with HRSD <10 | Clinically significant minor depression | 4 months | | NS
PROSPECT ^125,^ ^127^ | Percent with HRSD <10 | Clinically significant minor depression | 8 months | | NS
PROSPECT ^125,^ ^127^ | 12 months | | NS
PROSPECT ^125,^ ^127^ | Percent with HRSD <7 | All patients | 4 months | | OR 2.0, CI 1.0 to 3.8, p=.04
PROSPECT ^125,^ ^127^ | Percent with HRSD <7 | All patients | 8 months | | OR 2.1, CI 1.1 to 4.2, p=.02
PROSPECT ^125,^ ^127^ | Percent with HRSD <7 | 12 months | | NS
PROSPECT ^125,^ ^127^ | Percent with HRSD <7 | Major depression | 4 months | | OR 3.6, 95% CI 1.4; 9.4, p=.007
PROSPECT ^125,^ ^127^ | Percent with HRSD <7 | Major depression | 8 months | | OR 3.2, 95% CI 1.3; 7.9, p=.01
PROSPECT ^125,^ ^127^ | Percent with HRSD <7 | 12 months | | NS
PROSPECT ^125,^ ^127^ | Percent with HRSD <7 | Clinically significant minor depression | 4 months | | NS
PROSPECT ^125,^ ^127^ | Percent with HRSD <7 | Clinically significant minor depression | 8 months | | NS
12 months | | NS
RESPECT-D ^120^ | Percent with SCL-20 <0.5 | | 3 months | Intervention | OR 2.1, 95% CI 1.2; 3.7, p=.018
6 months | Intervention | OR 1.9, 95% CI 1.2; 3.3, p=.014
Datto, 2003 ^97^ | Percent below CES-D=16 (low level symptoms) | | 16 weeks | Intervention | OR 6.58, 95% CI 1.57; 27.03, p=.01
Datto, 2003 ^97^ | Percent below CES-D=11 | | 16 weeks | | NS
9 months | | NS
QuEST ^5^ | Percent below CES-D=16 | | 24 months | Intervention | P<.02 | Treatment × time
Katzelnick, 2000 ^100^ | Percent below Hamilton depression score<7 | | 12 months | Intervention | P<.001 | 27.7% compared to 12.8%
MEDICAL
Intermediate Level I (Depression)
IMPACT ^128,^ ^129^ | Arthritis pain intensity | | 3 months | Intervention | -0.58, 95% CI -0.9; -0.25, p<.001
IMPACT ^128,^ ^129^ | Arthritis pain intensity | | 6 months | | NS
IMPACT ^128,^ ^129^ | 12 months | Intervention | -0.53, 95% CI-0.92; -0.14, p=.009
IMPACT ^128,^ ^129^ | Arthritis interferes with daily activities | | 3 months | Intervention | -0.67, 95% CI -1.06; -0.27, p=.001
IMPACT ^128,^ ^129^ | Arthritis interferes with daily activities | | 6 months | Intervention | -0.56, 95% CI-0.96; -0.16, p=.006
IMPACT ^128,^ ^129^ | 12 months | Intervention | -0.59, CI -1 to -0.19, p=.004
IMPACT ^128,^ ^129^ | Arthritis pain interferes with daily activities | | 3 months | Intervention | -0.24, 95% CI -0.39; -0.09, p=.002
IMPACT ^128,^ ^129^ | Arthritis pain interferes with daily activities | | 6 months | Intervention | -0.22, 95% CI-0.36; -0.09, p=.005
IMPACT ^128,^ ^129^ | 12 months | Intervention | -0.26, 95% CI -0.41; -0.10, p=.002
IMPACT ^128,^ ^129^ | Graded chronic pain scale for arthritis pain severity | | 12 months | Intervention | Beta 0.15 (SE 0.06), p=.026 | Interaction: intervention × pain severity
IMPACT ^128,^ ^129^ | 12 months | | NS | Interaction: intervention × pain activity interference
IMPACT ^128,^ ^129^ | Graded chronic pain scale for arthritis pain activity interference | | 12 months | Intervention | Beta 0.14 (SE 0.07), p=.04 | Interaction: intervention × pain severity
12 months | | Beta 0.13 (SE 35), p=.015 | Interaction: intervention × pain activity interference
Pathways ^113^ | HbA1c level | | 6 months | | NS
12 months | | NS

Figure 5. Treatment response by level of provider integration

Figure 4. Symptom severity outcomes by level of provider integration

Figure 6. Remission rate by level of provider integration

Effect of levels of integration on outcomes: Process of care. Figures 7–9 are forest plots for symptom severity, response rates, and remission rates, respectively, for unpooled depression trials sorted by levels of process of care. The results are very similar to the plots for the levels of provider integration. There is no discernable effect of provider integration level on outcomes based on this data. IMPACT remains the standout positive trial for plotted symptom severity, while results are consistently positive across all levels of integration for treatment response and remission rates. Looking at the full set of trials listed in Table 9, which groups all trial outcomes by level of process of care and mental health illness category, it does not appear that excluding trials that did not report results in a usable format biased the results. The limited numbers of anxiety trials again exhibit a similar pattern. The results would not differ if the two low-quality trials (Swindle, Hilty) were not included in the analysis. ^85,^ ^105^ The pattern of results is also not affected by comparison group.

Table 9 Clinical outcomes by level of integrated proactive process of care

Outcome Project or Author | Measurement | Patient Category | Assessment Period | Direction of Effect | Effect Size | Comment
MENTAL ILLNESS SYMPTOMS (SEVERITY)
High Level (Depression)
Price, 2000 ^91^ | Shedler Quick Psycho Diagnostics Panel (Anxiety) | | 6 months | Intervention | P=.046
Hedrick, 2003 ^87^ | SCL-20 | | 3 months | Intervention | -0.17, 95% CI -0.31; -0.03, p<.05 | Equalized amount of treatment between collaborative and consult-liaison models; attention control
9 months | | NS
IMPACT ^2,^ ^179^ | SCL-20 | | 3 months | Intervention | -0.28, 95% CI -0.34; -0.21, p<.001
IMPACT ^2,^ ^179^ | SCL-20 | | 6 months | Intervention | -0.28, 95% CI -0.35; -0.19, p<.001
IMPACT ^2,^ ^179^ | SCL-20 | | 12 months | Intervention | NNT=4
IMPACT ^2,^ ^179^ | SCL-20 | | 18 months | Intervention | NNT=6
24 months | Intervention | NNT=9
Grypma, 2006 ^93^ | PHQ-9 score | All depression patients | 6 months | | NS | IMPACT intervention group compared to post-study integrated care group
Patients over 60 years | 6 months | | NS
Pathways ^113^ | SCL-20 | | 6 months | Intervention | OR 3.5, 95% CI 2.16; 5.68
12 months | Intervention | OR 3.5, 95% CI 2.14; 5.72
Clarke, 2005 ^83^ | CES-D | | 12 months | | NS | Study may have been under-powered to compare 2 active treatments. About 75% remission in both groups within 3 months.
Clarke, 2005 ^83^ | Hamilton Depression Rating Scale | | 12 months | | NS | Study may have been under-powered to compare 2 active treatments. About 75% remission in both groups within 3 months.
Youth Self Report | | 12 months | | NS
Katon, 2001 ^98^ | SCL-20 | | 12 months | | NS
Asarnow, 2005 ^114^ | CES-D | | 6 months | Intervention | -2.9, 95% CI -5.3; -0.4, p=.02
Percent with CES-D in severe range ≥24 | 6 months | Intervention | OR 0.6, 95% CI 0.4, 0.9, p=.02
High Level (Anxiety)
Price, 2000 ^91^ | Shedler Quick Psycho Diagnostics Panel (Anxiety) | | 6 months | Intervention | P=.046
CCAP ^9^ | Anxiety sensitivity index score | | 3 months | Intervention | Effect size 0.44
CCAP ^9^ | Anxiety sensitivity index score | | 6 months | Intervention | Effect size 0.45
CCAP ^9^ | Anxiety sensitivity index score | | 9 months | Intervention | Effect size 0.44
CCAP ^9^ | 12 months | Intervention | Effect size 0.43
CCAP ^9^ | CES-D | | 3 months | Intervention | Effect size 0.29
CCAP ^9^ | CES-D | | 6 months | Intervention | Effect size 0.29
CCAP ^9^ | CES-D | | 9 months | Intervention | Effect size 0.27
12 months | Intervention | Effect size 0.26
Rollman, 2005 ^101^ | PDSS Panic disorder severity scale | All patients | 12 months | Intervention | 0.33, 95% CI; 04 to 0.62, p=.02 | Intervention × time
Rollman, 2005 ^101^ | Panic disorder | 12 months | Intervention | 0.57, 95% CI 0.18; 0.96, p=.003 | Intervention × time
Rollman, 2005 ^101^ | *SIGH-A Hamilton anxiety rating scale | All patients | 12 months | Intervention | 0.38, 95% CI 0.09; 0.67, p=.03 | Intervention × time
Rollman, 2005 ^101^ | General anxiety disorder | 12 months | | NS
Hamilton depression rating scale | All patients | 12 months | Intervention | 0.57, 95% CI 0.25; 0.46, p=.03 | Intervention × time
Intermediate Level (Depression)
Swindle, 2003 ^85^ | Beck depression inventory | All patients | 3 months | | NS | No difference in outcomes for major depression or dysthymia. Several CNS were not voluntary, did not follow protocol, etc.
Swindle, 2003 ^85^ | Beck depression inventory | 12 months | | NS | | No difference in outcomes for major depression or dysthymia. Several CNS were not voluntary, did not follow protocol, etc.
Swindle, 2003 ^85^ | Beck depression inventory | Major depression | 3 months | | NS | No difference in outcomes for major depression or dysthymia. Several CNS were not voluntary, did not follow protocol, etc.
12 months | | NS
Simon, 2004 ^84^ | SCL-20 | Telephone psychotherapy plus care management | 6 months | Intervention | P<.001 | Difference between groups is equal to ½ of the SD of scores in general population
Simon, 2004 ^84^ | SCL-20 | Telephone care management | 6 months | Intervention | NS
9 months post-treatment | | NS
Boudreau, 2002 ^175^ | SCL-20 | | 12 months | | NS
PROSPECT ^125^ | Hamilton Depression Rating Scale | All patients | 4 months | | -3.5, 95% CI -4.7; -2.4, p<.001
PROSPECT ^125^ | Hamilton Depression Rating Scale | All patients | 8 months | | -2.1, 95% CI -3.4; -0.9, p<.001
PROSPECT ^125^ | Hamilton Depression Rating Scale | 12 months | | -1.8, 95% CI -3.1; -0.5, p=.006
PROSPECT ^125^ | Hamilton Depression Rating Scale | Major depression | 4 months | | -4.6, 95% CI -6.2; -3.1, p<.001
PROSPECT ^125^ | Hamilton Depression Rating Scale | Major depression | 8 months | | -2.5, 95% CI -4.1; -0.9, p.003
PROSPECT ^125^ | Hamilton Depression Rating Scale | 12 months | | -2.1, 95% CI -3.7; -0.4, p=.02
PROSPECT ^125^ | Hamilton Depression Rating Scale | Clinically significant minor depression | 4 months | | NS
PROSPECT ^125^ | Hamilton Depression Rating Scale | Clinically significant minor depression | 8 months | | NS
12 months | | NS
Tutty, 2000 ^89^ | SCL-20 | | 3 months | Intervention | P=.03
6 months | Intervention | P=.03
RESPECT-D ^120^ | SCL-20 | | 3 months | Intervention | -0.16, 95% CI -0.32; -0.002, p=.048
6 months | Intervention | -0.20, CI -0.39 to -0.014, p=.036
Adler, 2004 ^106^ | Modified Beck depression inventory | | 3 months | | NS
6 months | | NS
Partners in Care ^122,^ ^123^ | Percent with probable depression based on CIDI screen | QI-Meds | 6 months | Intervention | P<.05 | Time trends: Percent of usual care with probable depression dropped from 6 to 24 months while QI-Meds climbed. QI therapy remained relatively flat. QI meds significantly higher than QI therapy at 24 months.
Partners in Care ^122,^ ^123^ | Percent with probable depression based on CIDI screen | QI-Meds | 12 months | Intervention | P<.05
Partners in Care ^122,^ ^123^ | Percent with probable depression based on CIDI screen | QI-Meds | 18 months | | NS
Partners in Care ^122,^ ^123^ | 24 months | | NS
Partners in Care ^122,^ ^123^ | Overall poor outcome: patient scored depressed if score in depressed range of all 3 CIDI screen, full 12-month CIDI, and CES-D, vs. 2 or fewer measures. | QI-Meds | 6 months | | NS
Partners in Care ^122,^ ^123^ | Overall poor outcome: patient scored depressed if score in depressed range of all 3 CIDI screen, full 12-month CIDI, and CES-D, vs. 2 or fewer measures. | QI-Meds | 12 months | | NS
Partners in Care ^122,^ ^123^ | Overall poor outcome: patient scored depressed if score in depressed range of all 3 CIDI screen, full 12-month CIDI, and CES-D, vs. 2 or fewer measures. | QI-Meds | 18 months | | NS
24 months | | NS
QuEST ^124^ | Modified CES-D | Patients beginning new treatment episode | 6 months | Intervention | Effect size = 0.43
QuEST ^124^ | Modified CES-D | Patients recently treated | 6 months | | NS
Patients beginning new treatment episode, who find antidepressants acceptable | 6 months | Intervention | Effect size = 0.83 | This patient group also showed improvement in physical functioning, SF12 PCS, and satisfaction with care
Simon, 2000 ^99^ | SCL-20 | Care management arm | 6 months | Intervention | P=.008
Katzelnick, 2000 ^100^ | Hamilton depression score | | 3 months | Intervention | P=.04 | Significant group × time as well
Katzelnick, 2000 ^100^ | Hamilton depression score | | 6 months | Intervention | P<.001 | Significant group × time as well
12 months | Intervention | P=.005
Intermediate Level (Anxiety)
Roy-Byrne, 2001 ^109^ | PDSS Panic disorder severity scale | | 3 months | | NS | Intervention × time p=.05, driven by reduction in anticipatory anxiety
Roy-Byrne, 2001 ^109^ | PDSS Panic disorder severity scale | | 6 months | Intervention | P=.003 | Intervention × time p=.05, driven by reduction in anticipatory anxiety
Roy-Byrne, 2001 ^109^ | PDSS Panic disorder severity scale | | 9 months | | NS | Intervention × time p=.05, driven by reduction in anticipatory anxiety
Roy-Byrne, 2001 ^109^ | 12 months | | NS
Roy-Byrne, 2001 ^109^ | Anxiety sensitivity scale | | 3 months | Intervention | P=.002 | Intervention × time p=.018
Roy-Byrne, 2001 ^109^ | Anxiety sensitivity scale | | 6 months | Intervention | P<.001 | Intervention × time p=.018
Roy-Byrne, 2001 ^109^ | Anxiety sensitivity scale | | 9 months | | NS | Intervention × time p=.018
Roy-Byrne, 2001 ^109^ | 12 months | Intervention | P=.035
Roy-Byrne, 2001 ^109^ | Panic related agoraphobic avoidance | | 12 months | | NS
Roy-Byrne, 2001 ^109^ | Fear Questionnaire agoraphobic subscale | | 12 months | | NS
Roy-Byrne, 2001 ^109^ | CES-D | | 3 months | Intervention | P=.002 | Intervention × time p=.03
Roy-Byrne, 2001 ^109^ | CES-D | | 6 months | Intervention | P=.005
Roy-Byrne, 2001 ^109^ | CES-D | | 9 months | Intervention | P=.036
12 months | Intervention | P=.02
Low Level (Depression)
Finley, 2003 ^108^ | Brief inventory for depressive symptoms | | 6 months | | NS
Katon, 1999 ^3,^ ^103^ | SCL-20 | All patients | 3 months | Intervention | P=.003
Katon, 1999 ^3,^ ^103^ | SCL-20 | 6 months | Intervention | P=.04 | Treatment × time
Katon, 1999 ^3,^ ^103^ | SCL-20 | All patients | 28 months | Intervention | P=.05 | Treatment × time
Katon, 1999 ^3,^ ^103^ | SCL-20 | Moderate severity | 28 months | Intervention | P=.004 | Treatment × time
High severity | 28 months | | NS
Lin, 1999 ^4^ (followup of Katon, 1995 and Katon, 1996) | SCL-20 | | 19 months | | NS
Inventory for depressive symptomatology | | 19 months | | NS
Partners in Care ^122,^ ^123^ | Percent with probable depression based on CIDI screen | All interventions | 6 months | Any intervention | P=.001
Partners in Care ^122,^ ^123^ | Percent with probable depression based on CIDI screen | 12 months | Any intervention | P=.005
Partners in Care ^122,^ ^123^ | Percent with probable depression based on CIDI screen | QI-Therapy | 6 months | Intervention | P<.05
Partners in Care ^122,^ ^123^ | Percent with probable depression based on CIDI screen | QI-Therapy | 12 months | Intervention | P<.05
Partners in Care ^122,^ ^123^ | Percent with probable depression based on CIDI screen | QI-Therapy | 18 months | | NS
Partners in Care ^122,^ ^123^ | 24 months | | NS
Partners in Care ^122,^ ^123^ | Overall poor outcome: patient scored depressed if score in depressed range of all 3 CIDI screen, full 12-month CIDI, and CES-D, vs. 2 or fewer measures. | QI-Therapy | 6 months | Intervention | P<.05
Partners in Care ^122,^ ^123^ | Overall poor outcome: patient scored depressed if score in depressed range of all 3 CIDI screen, full 12-month CIDI, and CES-D, vs. 2 or fewer measures. | QI-Therapy | 12 months | Intervention | P<.05
Partners in Care ^122,^ ^123^ | Overall poor outcome: patient scored depressed if score in depressed range of all 3 CIDI screen, full 12-month CIDI, and CES-D, vs. 2 or fewer measures. | QI-Therapy | 18 months | Intervention, usual care and QI-Meds | P<.05
24 months | Intervention, QI-Meds | P<.05
Hunkeler, 2000 ^110^ (reporting telehealth nurse only, not peer support) | Hamilton depression rating score | | 6 weeks | | NS
Hunkeler, 2000 ^110^ (reporting telehealth nurse only, not peer support) | 6 months | Intervention | P=.006
Hunkeler, 2000 ^110^ (reporting telehealth nurse only, not peer support) | Beck depression rating score | | 6 weeks | | NS
6 months | | NS
Low Level (Other Disorders)
Katon, 1992 ^107^ | SCL somatization | | 6 months | | NS
Katon, 1992 ^107^ | 12 months | | NS
Katon, 1992 ^107^ | SCL depression | | 6 months | | NS
Katon, 1992 ^107^ | 12 months | | NS
Katon, 1992 ^107^ | SCL anxiety | | 6 months | | NS
12 months | | NS
TREATMENT RESPONSE
High Level(Depression)
Hedrick, 2003 ^87^ | Percent with 50% improvement in SCL-20 | | 3 months | | NS
9 months | | NS
IMPACT ^2,^ ^179^ | Percent with 50% improvement in SCL-20 | | 3 months | Intervention | 2.73, 95% CI 2.10; 3.54, p<.001
IMPACT ^2,^ ^179^ | Percent with 50% improvement in SCL-20 | | 6 months | Intervention | 2.21, 95% CI 1.76; 2.76, p<.001
IMPACT ^2,^ ^179^ | Percent with 50% improvement in SCL-20 | | 12 months | Intervention | 26.85, 95% CI 22.34; 31.35, p<.0001
IMPACT ^2,^ ^179^ | Percent with 50% improvement in SCL-20 | | 18 months | Intervention | 16.99, 95% CI 12.34; 21.64, p<.0001
24 months | Intervention | 10.87, 95% CI 6.16; 15.57, p<.0001
Fortney, 2006 ^92^ | Percent with 50% improvement in SCL-20 | | 6 months | Intervention | NNT=11
12 months | Intervention | NS
Pathways ^113^ | Percent with 50% improvement in SCL-90 | | 6 months | | NS
12 months | | NS
Grypma, 2006 ^93^ | Percent with 50% improvement in PHQ-9 | All depression patients | 6 months | | NS | IMPACT intervention group compared to post-study integrated care group.
Patients over 60 years | 6 months | | NS
PROSPECT ^125,^ ^127^ | Percent with 50% improvement in HRSD | All patients | 4 months | | OR 2.7, 95% CI 1.5; 4.9, p=.001 | At 8 months, patients taking medication only showed more improvement than patients with IPT only, P=.02
PROSPECT ^125,^ ^127^ | Percent with 50% improvement in HRSD | All patients | 8 months | | OR 2.1, 95% CI 1.1; 3.8, p=.02 | At 8 months, patients taking medication only showed more improvement than patients with IPT only, P=.02
PROSPECT ^125,^ ^127^ | Percent with 50% improvement in HRSD | 12 months | | OR 2.0, 95% CI 1.1; 3.8P=.02
PROSPECT ^125,^ ^127^ | Percent with 50% improvement in HRSD | Major depression | 4 months | | OR 3.9, 95% CI 1.8; 8.5, p<.001
PROSPECT ^125,^ ^127^ | Percent with 50% improvement in HRSD | Major depression | 8 months | | OR 3.0, 95% CI 1.4; 6.4P=.006
PROSPECT ^125,^ ^127^ | Percent with 50% improvement in HRSD | 12 months | | NS
PROSPECT ^125,^ ^127^ | Percent with 50% improvement in HRSD | Clinically significant minor depression | 4 months | | NS
PROSPECT ^125,^ ^127^ | Percent with 50% improvement in HRSD | Clinically significant minor depression | 8 months | | NS
12 months | | NS
Katon, 1996 ^88^ | Percent with 50% improvement in SCL-20 | Major depression | 4 months | Intervention | P=.002 | Group × time trend
Katon, 1996 ^88^ | Percent with 50% improvement in SCL-20 | 7 months | Intervention | P=.04 | Group × time trend
Katon, 1996 ^88^ | Percent with 50% improvement in SCL-20 | Minor depression | 4 months | | NS
7 months | | NS
High Level (Anxiety)
Rollman, 2005 ^101^ | 40% reduction in SIGH-A | All patients | 12 months | Intervention | 30.8, 95% CI 17.0; 44.7, p<.001
Rollman, 2005 ^101^ | General anxiety disorder | 12 months | | NS
Rollman, 2005 ^101^ | 40% reduction in PDSS | All patients | 12 months | Intervention | 20.7, 95% CI 9.7; 31.5, p<.001
Rollman, 2005 ^101^ | Panic disorder | 12 months | Intervention | 32.2, 95% CI 15.5; 48.9, p<.001
40% reduction in Hamilton depression rating | All patients | 12 months | Intervention | 28.5, 95% CI 15; 42.6, p<.001
Intermediate Level (Depression)
Simon, 2004 ^84^ | Percent with 50% improvement in SCL-20 | Telephone care management | 6 months | Intervention | NS | Usual care as comparison
Telephone psychotherapy plus care management | 6 months | Intervention | NNT=6.4 | Usual care as comparison
Tutty, 2000 ^89^ | Percent with 50% improvement in SCL-20 | | 3 months | | NS
6 months | | NS
RESPECT-D ^120^ | Percent with 50% improvement in SCL-20 | | 3 months | Intervention | OR 2.2, 95% CI 1.4; 3.4, p=.001
6 months | Intervention | OR 1.7, 95% CI 1.1; 2.7, p=.021
Finley, 2003 ^108^ | Percent with 50% improvement in brief inventory for depressive symptoms | | 6 months | | NS
Datto, 2003 ^97^ | Percent with 50% improvement in CES-D | | 16 weeks | | NS
Datto, 2003 ^97^ | Percent with 50% improvement in Beck depression rating score | | 6 weeks | | NS
| 6 months | | P=.05
Simon, 2000 ^99^ | Percent with 50% improvement in SCL-20 | Care management arm | 6 months | Intervention | OR 2.22, 95% CI 1.31; 3.75
Katzelnick, 2000 ^100^ | Percent with 50% improvement in Hamilton depression score | | 12 months | Intervention | P<.001 | 53.2% compared to 32.8%
Intermediate Level (Anxiety)
Roy-Byrne, 2001 ^109^ | 40% reduction in PDSS | | 3 months | | NS
Roy-Byrne, 2001 ^109^ | 40% reduction in PDSS | | 6 months | Intervention | P=.001
Roy-Byrne, 2001 ^109^ | 40% reduction in PDSS | | 9 months | | NS
12 months | Intervention | P=.048
Low Level (Depression)
Hunkeler, 2000 ^110^ (reporting telehealth nurse only, not peer support) | Percent with 50% improvement in Hamilton depression rating score | | 6 weeks | Intervention | P=.01
6 months | Intervention | P=.003
REMISSION
High Level (Depression)
Katon, 1999 ^103^ | Percent with SCID ≤1 | | 3 months | Intervention | P=.01
6 months | Intervention | P=.05
Hedrick, 2003 ^87^ | Percent with SCL-20 ≥1.75 | | 3 months | | NS | Collaborative care patients with baseline scores above 1.75 were significantly less likely to be above 1.75 at 3 months.
Fortney, 2006 ^92^ | Percent with SCL-20 <0.5 | | 6 months | | NS
12 months | Intervention | NNT=11
IMPACT ^2,^ ^121^ | Percent with SCL-20 <0.5 | | 3 months | Intervention | 3.63, 95% CI 2.46; 5.38, p<.001
IMPACT ^2,^ ^121^ | Percent with SCL-20 <0.5 | | 6 months | Intervention | 2.16, 95% CI 1.69; 2.76, p<.001
IMPACT ^2,^ ^121^ | Percent with SCL-20 <0.5 | | 12 months | Intervention | 17.48, 95% CI 13.78; 21.18, p<.0001
IMPACT ^2,^ ^121^ | Percent with SCL-20 <0.5 | | 18 months | Intervention | 9.31, 95% CI 5.77; 12.85, p<.0001
IMPACT ^2,^ ^121^ | 24 months | Intervention | 5.65, 95% CI 2.12; 9.17, p=.0018
Percent with SCID ≤1 | | 6 months | Intervention | OR 0.50, 95% CI 0.40; 0.62, P<.001
PROSPECT ^125,^ ^127^ | Percent with HRSD <10 | All patients | 4 months | Intervention | OR 3.7, 95% CI 1.7; 7.7, p=<.001 | Treatment × time p<.01 for medication only, vs. IPT only
PROSPECT ^125,^ ^127^ | Percent with HRSD <10 | All patients | 8 months | | NS | Treatment × time p<.01 for medication only, vs. IPT only
PROSPECT ^125,^ ^127^ | Percent with HRSD <10 | 12 months | | NS
PROSPECT ^125,^ ^127^ | Percent with HRSD <10 | Major depression | 4 months | Intervention | OR 6.7, 95% CI 2.5; 17.9, p<.001
PROSPECT ^125,^ ^127^ | Percent with HRSD <10 | Major depression | 8 months | | NS
PROSPECT ^125,^ ^127^ | Percent with HRSD <10 | 12 months | | NS
PROSPECT ^125,^ ^127^ | Percent with HRSD <10 | Clinically significant minor depression | 4 months | | NS
PROSPECT ^125,^ ^127^ | Percent with HRSD <10 | Clinically significant minor depression | 8 months | | NS
PROSPECT ^125,^ ^127^ | 12 months | | NS
PROSPECT ^125,^ ^127^ | Percent with HRSD <7 | All patients | 4 months | Intervention | OR 2.0, 95% CI 1.0; 3.8, p=.04
PROSPECT ^125,^ ^127^ | Percent with HRSD <7 | All patients | 8 months | Intervention | OR 2.1, 95% CI 1.1; 4.2, p=.02
PROSPECT ^125,^ ^127^ | Percent with HRSD <7 | 12 months | | NS
PROSPECT ^125,^ ^127^ | Percent with HRSD <7 | Major depression | 4 months | Intervention | OR 3.6, 95% CI 1.4; 9.4, p=.007
PROSPECT ^125,^ ^127^ | Percent with HRSD <7 | Major depression | 8 months | Intervention | OR 3.2, 95% CI 1.3; 7.9, p=.01
PROSPECT ^125,^ ^127^ | Percent with HRSD <7 | 12 months | | NS
PROSPECT ^125,^ ^127^ | Percent with HRSD <7 | Clinically significant minor depression | 4 months | | NS
PROSPECT ^125,^ ^127^ | Percent with HRSD <7 | Clinically significant minor depression | 8 months | | NS
12 months | | NS
High Level (Anxiety)
CCAP ^9^ | Anxiety sensitivity score <20 | | 3 months | Intervention | Effect size 0.40
CCAP ^9^ | Anxiety sensitivity score <20 | | 6 months | Intervention | Effect size 0.48
CCAP ^9^ | Anxiety sensitivity score <20 | | 9 months | Intervention | Effect size 0.47
CCAP ^9^ | 12 months | Intervention | Effect size 0.51
CCAP ^9^ | High end-state functioning | | 3 months | Intervention | Effect size 0.23
CCAP ^9^ | High end-state functioning | | 6 months | Intervention | Effect size 0.29
CCAP ^9^ | High end-state functioning | | 9 months | Intervention | Effect size 0.32
12 months | Intervention | Effect size 0.34
Price, 2000 ^91^ | Shedler quick diagnostics panel <10 (anxiety) | | 6 months | Intervention | P=.025 | 55.6% intervention vs. 22.8% control achieved remission
Intermediate Level (Depression)
Boudreau, 2002 ^175^ | Percent with major depression as measured with SCID | | 12 months | | NS
Tutty, 2000 ^89^ | Percent with SCID ≤1 | | 3 months | | NS
6 months | | NS
Partners in Care ^122,^ ^123^ | Percent with modified CES-D <20 | | 6 months | All interventions | P=.005
Partners in Care ^122,^ ^123^ | 12 months | All interventions | P=.04
Percent without clinical diagnosis, based on full 12-month CIDI | | 2 years | QI-therapy vs. QI-meds | P=.04
RESPECT-D ^120^ | Percent with SCL-20 <0.5 | | 3 months | Intervention | OR 2.1, 95% CI 1.2; 3.7, p=.018
6 months | Intervention | OR 1.9, 95% CI 1.2; 3.3, p=.014
Datto, 2003 ^97^ | Percent below CES-D=16 (low level symptoms) | | 16 weeks | Intervention | OR 6.58, CI 1.57 to 27.03, p=.01
Datto, 2003 ^97^ | Percent below CES-D=11 | | 16 weeks | | NS
9 months | | NS
QuEST ^5^ | Percent below CES-D=16 | | 24 months | Intervention | P<.02 | Treatment × time
Katzelnick, 2000 ^100^ | Percent below Hamilton depression score<7 | | 12 months | Intervention | P<.001 | 27.7% compared to 12.8%
Intermediate Level (Anxiety)
Roy-Byrne, 2001 ^109^ | Anxiety sensitivity score <20 | | 3 months | Intervention | P=.004
Roy-Byrne, 2001 ^109^ | Anxiety sensitivity score <20 | | 6 months | Intervention | P=.004
Roy-Byrne, 2001 ^109^ | Anxiety sensitivity score <20 | | 9 months | | NS
12 months | Intervention | P=.005
Low Level (Depression)
Finley, 2003 ^108^ | Percent with brief inventory for depressive symptoms <9 | | 6 months | | NS
MEDICAL
High Level (Depression)
IMPACT ^128,^ ^129^ | Arthritis pain intensity | | 3 months | Intervention | -0.58, 95% CI -0.9; -0.25, p<.001
IMPACT ^128,^ ^129^ | Arthritis pain intensity | | 6 months | | NS
IMPACT ^128,^ ^129^ | 12 months | Intervention | -0.53, 95% CI-0.92; -0.14, p=.009
IMPACT ^128,^ ^129^ | Arthritis interferes with daily activities | | 3 months | Intervention | -0.67, 95% CI -1.06; -0.27, p=.001
IMPACT ^128,^ ^129^ | Arthritis interferes with daily activities | | 6 months | Intervention | -0.56, 95% CI -0.96; -0.16, p=.006
IMPACT ^128,^ ^129^ | 12 months | Intervention | -0.59, 95% CI -1; -0.19, p=.004
IMPACT ^128,^ ^129^ | Arthritis pain interferes with daily activities | | 3 months | Intervention | -0.24, 95% CI -0.39; -0.09, p=.002
IMPACT ^128,^ ^129^ | Arthritis pain interferes with daily activities | | 6 months | Intervention | -0.22, 95% CI -0.36; -0.09, p=.005
IMPACT ^128,^ ^129^ | 12 months | Intervention | -0.26, 95% CI -0.41; -0.10, p=.002
IMPACT ^128,^ ^129^ | Graded chronic pain scale for arthritis pain severity | | 12 months | Intervention | Beta 0.15 (SE 0.06), p=.026 | Interaction: intervention × pain severity
IMPACT ^128,^ ^129^ | 12 months | | NS | Interaction: intervention × pain activity interference
IMPACT ^128,^ ^129^ | Graded chronic pain scale for arthritis pain activity interference | | 12 months | Intervention | Beta 0.14 (SE 0.07), p=.04 | Interaction: intervention × pain severity
12 months | Intervention | Beta 0.13 (SE 35), p=.015 | Interaction: intervention × pain activity interference
Pathways ^113^ | HbA1c level | | 6 months | | NS
12 months | | NS

Figure 8. Treatment response by level of integrated process of care

Figure 7. Symptom severity outcomes by level of integrated process of care

Figure 9. Remission rate by level of integrated process of care

Research on the relative contribution of each element of the care process to improved outcomes is limited, which is why a simple additive approach was used in this analysis. We also performed a sensitivity analysis of the approach by combining expert estimations of relative weights of the components. All expert responses were treated with equal weight in the combined score. The resulting weighted scores did not materially affect the rankings of the trials. Given the low variability in use of supervision across the studies, using Bower et al's. meta-analysis of “active ingredients” in collaborative care (which included international studies with large patient samples) would have reduced the list of elements to merely the presence of screening, an approach deemed insufficient for this analysis. ^60^

Effect of levels of integration on outcomes: Matrix integration. Figures 10–12 are forest plots for symptom severity, response rates, and remission rates, respectively, for unpooled depression trials sorted by matrix levels of integration. There were a small number of trials in each matrix cell integration level and several cells did not have representative studies. Given that, the matrix integration provides a view of integration that may provide a more refined gradient. Again, with the available plotted data, there is no discernable effect of matrix integration level on outcomes based on this data, and the results would not differ if the two low quality trials were not included in the analysis. ^85,^ ^105^ The pattern of results is also not affected by comparison group. The anxiety trials are so limited that a matrix analysis is not tenable.

Figure 11. Treatment response by matrix level of integration

Figure 10. Symptom severity by matrix level of integration

Figure 12. Remission by matrix level of integration

PRISM-E trial. The PRISM-E study ^82^ was a multisite randomized comparative trial funded by an interagency collaboration including the Substance Abuse and Mental Health Services Administration (SAMHSA), the Veteran's Administration (VA), the Health Resources and Services Administration (HRSA), and the Center for Medicare and Medicaid Services (CMS). The trial examined two models of care for three common mental health concerns for the elderly; depression, anxiety, and at-risk drinking. To be eligible to participate in the integrated treatment model arm, clinics had to exhibit a number of features, including co-location of available mental health services provided by licensed mental health providers with formal communication linkages. To be eligible to participate in the enhanced referral model arm, clinics had to exhibit strong communication and monitoring linkages with, and ensure transportation to, available specialty mental health clinics. Both study arms are considered integrated care by this review's operational definitions, since they both involve linkages between primary care and mental health specialty providers. However, as mentioned above, the participating clinics did not have mandated standardized depression treatment algorithms or interventions other than the brief alcohol intervention.

Results from this direct comparison of integration and enhanced referral in real world settings (Table 10) suggest that enhanced referral had improved outcomes for major depression, while outcomes for other forms of depression or all patients showed no difference between treatment arms. ^118^ Secondary analysis suggested that the combination of talk therapy plus medication worked better for major depression patients in the enhanced referral model. A critical advantage provided by specialty mental health settings is the full range of psychotherapeutic options, which is generally unavailable in a busy primary care clinic. ^118^ There were no reported results based on anxiety alone or anxiety and alcohol as comorbidities with depression.

Table 10 Clinical outcomes by mental illness

Outcome Project or Author | Measurement | Patient Category | Assessment Period | Direction of Effect | Results | Comment
DEPRESSION
Depression symptoms (severity)
PRISM-E ^118^ | CES-D score | Major depression | 3 months | Enhanced referral | NS | Secondary analysis showed combination of talk therapy plus medication worked better in enhanced referral than integrated care model for patients with major depression.
PRISM-E ^118^ | CES-D score | 6 months | Enhanced referral | Mean 2.8, 95% CI 1.0; 4.5, p=.003 | | Secondary analysis showed combination of talk therapy plus medication worked better in enhanced referral than integrated care model for patients with major depression.
PRISM-E ^118^ | CES-D score | Other depression | 3 months | | NS | Secondary analysis showed combination of talk therapy plus medication worked better in enhanced referral than integrated care model for patients with major depression.
PRISM-E ^118^ | CES-D score | 6 months | | NS | | Secondary analysis showed combination of talk therapy plus medication worked better in enhanced referral than integrated care model for patients with major depression.
PRISM-E ^118^ | CES-D score | All depression | 3 months | | NS | Secondary analysis showed combination of talk therapy plus medication worked better in enhanced referral than integrated care model for patients with major depression.
6 months | | NS
Grypma, 2006 ^93^ | PHQ-9 score | All depression patients | 6 months | | NS | IMPACT intervention group compared to post-study integrated care group.
Patients over 60 years | 6 months | | NS
IMPACT ^2,^ ^121^ | SCL-20 | | 3 months | Intervention | -0.28, 95% CI -0.34; -0.21, p<.001
IMPACT ^2,^ ^121^ | SCL-20 | | 6 months | Intervention | -0.28, 95% CI -0.35; -0.19, p<.001
IMPACT ^2,^ ^121^ | SCL-20 | | 12 months | Intervention | NNT=4
IMPACT ^2,^ ^121^ | SCL-20 | | 18 months | Intervention | NNT=6
24 months | Intervention | NNT=9
Clarke, 2005 ^180^ | CES-D | | 12 months | | NS | Study may have been under-powered to compare 2 active treatments. About 75% remission in both groups within 3 months.
Clarke, 2005 ^180^ | Hamilton Depression Rating Scale | | 12 months | | NS | Study may have been under-powered to compare 2 active treatments. About 75% remission in both groups within 3 months.
Youth Self Report | | 12 months | | NS
Pathways ^113^ | SCL-20 | | 6 months | Intervention | OR 3.5, 95% CI 2.16; 5.68
12 months | Intervention | OR 3.5, 95% CI 2.14; 5.72
PROSPECT ^125^ | Hamilton Depression Rating Scale | All patients | 4 months | | -3.5, 95% CI -4.7; -2.4, p<.001
PROSPECT ^125^ | Hamilton Depression Rating Scale | All patients | 8 months | | -2.1, 95% CI -3.4; -0.9, p<.001
PROSPECT ^125^ | Hamilton Depression Rating Scale | 12 months | | -1.8, 95% CI -3.1; -0.5, p=.006
PROSPECT ^125^ | Hamilton Depression Rating Scale | Major depression | 4 months | | -4.6, 95% CI -6.2; -3.1, p<.001
PROSPECT ^125^ | Hamilton Depression Rating Scale | Major depression | 8 months | | -2.5, CI -4.1 to -0.9, p.003
PROSPECT ^125^ | Hamilton Depression Rating Scale | 12 months | | -2.1, 95% CI -3.7; -0.4, p=.02
PROSPECT ^125^ | Hamilton Depression Rating Scale | Clinically significant minor depression | 4 months | | NS
PROSPECT ^125^ | Hamilton Depression Rating Scale | Clinically significant minor depression | 8 months | | NS
12 months | | NS
RESPECT-D ^120^ | SCL-20 | | 3 months | Intervention | -0.16, 95% CI -0.32; -0.002, p=.048
6 months | Intervention | -0.20, 95% CI -0.39; -0.014, p=.036
Simon, 2004 ^84^ | SCL-20 | Telephone psychotherapy plus care management | 6 months | Intervention | P<.001 | Difference between groups is equal to ½ of the SD of scores in general population
Telephone care management | 6 months | Intervention | NS
Adler, 2004 ^106^ | Modified Beck depression inventory | | 3 months | | NS
6 months | | NS
Finley, 2003 ^108^ | Brief inventory for depressive symptoms | | 6 months | | NS
Swindle, 2003 ^85^ | Beck depression inventory | All patients | 3 months | | NS | No difference in outcomes for major depression or dysthymia.
Swindle, 2003 ^85^ | Beck depression inventory | 12 months | | NS | | No difference in outcomes for major depression or dysthymia.
Swindle, 2003 ^85^ | Beck depression inventory | Major depression | 3 months | | NS | No difference in outcomes for major depression or dysthymia.
12 months | | NS
Partners in Care ^6,^ ^122,^ ^123^ | Percent with probable depression based on CIDI screen | All interventions | 6 months | Any intervention | P=.001
Partners in Care ^6,^ ^122,^ ^123^ | Percent with probable depression based on CIDI screen | All interventions | 12 months | Any intervention | P=.005
Partners in Care ^6,^ ^122,^ ^123^ | Percent with probable depression based on CIDI screen | 5 years | Any intervention | 6.6, 95% CI 0.4; 12.8, p=.04
Partners in Care ^6,^ ^122,^ ^123^ | Percent with probable depression based on CIDI screen | QI-Meds | 6 months | Intervention | P<.05 | Time trends: Percent of usual care with probable depression dropped from 6 to 24 months while QI-Meds climbed. QI-therapy remained relatively flat. QI-meds significantly higher than QI-therapy at 24 months.
Partners in Care ^6,^ ^122,^ ^123^ | Percent with probable depression based on CIDI screen | QI-Meds | 12 months | Intervention | P<.05
Partners in Care ^6,^ ^122,^ ^123^ | Percent with probable depression based on CIDI screen | QI-Meds | 18 months | | NS
Partners in Care ^6,^ ^122,^ ^123^ | Percent with probable depression based on CIDI screen | QI-Meds | 24 months | | NS
Partners in Care ^6,^ ^122,^ ^123^ | Percent with probable depression based on CIDI screen | 5 years | | NS
Partners in Care ^6,^ ^122,^ ^123^ | Percent with probable depression based on CIDI screen | QI-Therapy | 6 months | Intervention | P<.05
Partners in Care ^6,^ ^122,^ ^123^ | Percent with probable depression based on CIDI screen | QI-Therapy | 12 months | Intervention | P<.05
Partners in Care ^6,^ ^122,^ ^123^ | Percent with probable depression based on CIDI screen | QI-Therapy | 18 months | | NS
Partners in Care ^6,^ ^122,^ ^123^ | Percent with probable depression based on CIDI screen | QI-Therapy | 24 months | | NS
Partners in Care ^6,^ ^122,^ ^123^ | 5 years | Intervention | P=.05
Partners in Care ^6,^ ^122,^ ^123^ | Overall poor outcome: patient scored depressed if score in depressed range of all 3 CIDI screen, full 12-month CIDI, and CES-D, vs. 2 or fewer measures. | QI-Meds | 6 months | | NS
Partners in Care ^6,^ ^122,^ ^123^ | Overall poor outcome: patient scored depressed if score in depressed range of all 3 CIDI screen, full 12-month CIDI, and CES-D, vs. 2 or fewer measures. | QI-Meds | 12 months | | NS
Partners in Care ^6,^ ^122,^ ^123^ | Overall poor outcome: patient scored depressed if score in depressed range of all 3 CIDI screen, full 12-month CIDI, and CES-D, vs. 2 or fewer measures. | QI-Meds | 18 months | | NS
Partners in Care ^6,^ ^122,^ ^123^ | Overall poor outcome: patient scored depressed if score in depressed range of all 3 CIDI screen, full 12-month CIDI, and CES-D, vs. 2 or fewer measures. | 24 months | | NS
Partners in Care ^6,^ ^122,^ ^123^ | Overall poor outcome: patient scored depressed if score in depressed range of all 3 CIDI screen, full 12-month CIDI, and CES-D, vs. 2 or fewer measures. | QI-Therapy | 6 months | Intervention | P<.05
Partners in Care ^6,^ ^122,^ ^123^ | Overall poor outcome: patient scored depressed if score in depressed range of all 3 CIDI screen, full 12-month CIDI, and CES-D, vs. 2 or fewer measures. | QI-Therapy | 12 months | Intervention | P<.05
Partners in Care ^6,^ ^122,^ ^123^ | Overall poor outcome: patient scored depressed if score in depressed range of all 3 CIDI screen, full 12-month CIDI, and CES-D, vs. 2 or fewer measures. | QI-Therapy | 18 months | Intervention, usual care and QI-meds | P<.05
24 months | Intervention, QI-meds | P<.05
Hedrick 2003 ^87^ | SCL-20 | | 3 months | Intervention | -0.17, 95% CI -0.31; -0.03, p<.05 | Equalized amount of treatment between collaborative and consult-liaison models; attention control
9 months | | NS
Katon, 1999 ^3,^ ^103^ | SCL-20 | All patients | 3 months | Intervention | P=.003
Katon, 1999 ^3,^ ^103^ | SCL-20 | 6 months | Intervention | P=.04 | Treatment × time
Katon, 1999 ^3,^ ^103^ | SCL-20 | All patients | 28 months | Intervention | P=.05 | Treatment × time
Katon, 1999 ^3,^ ^103^ | SCL-20 | Moderate severity | 28 months | Intervention | P=.004 | Treatment × time
High severity | 28 months | | NS
Lin, 1999 ^4^ (followup of Katon, 1995 and Katon, 1996) | SCL-20 | | 19 months | | NS
Inventory for depressive symptomatology | | 19 months | | NS
Katon, 2001 ^98^ | SCL-20 | | 12 months | | NS
Boudreau, 2002 ^175^ | SCL-20 | | 12 months | | NS
Tutty, 2000 ^89^ | SCL-20 | | 3 months | Intervention | P=.03
6 months | Intervention | P=.03
Hunkeler, 2000 ^110^ (reporting telehealth nurse only, not peer support) | Hamilton depression rating score | | 6 weeks | | NS
Hunkeler, 2000 ^110^ (reporting telehealth nurse only, not peer support) | 6 months | Intervention | P=.006
Hunkeler, 2000 ^110^ (reporting telehealth nurse only, not peer support) | Beck depression rating score | | 6 weeks | | NS
6 months | | NS
QuEST ^124^ | Modified CES-D | Patients beginning new treatment episode | 6 months | Intervention | Effect size = 0.43
QuEST ^124^ | Modified CES-D | Patients recently treated | 6 months | | NS
Patients beginning new treatment episode, who find antidepressants acceptable | 6 months | Intervention | Effect size = 0.83 | This patient group also showed improvement in physical functioning, SF12 PCS, and satisfaction with care
Simon, 2000 ^99^ | SCL-20 | Care management arm | 6 months | Intervention | P=.008
Katzelnick, 2000 ^100^ | Hamilton depression score | | 3 months | Intervention | P=.04 | Significant group × time as well
Katzelnick, 2000 ^100^ | Hamilton depression score | | 6 months | Intervention | P<.001 | Significant group × time as well
12 months | Intervention | P=.005
Asarnow, 2005 ^114^ | CES-D | | 6 months | Intervention | -2.9, 95% CI -5.3; -0.4, p=.02
Percent with CES-D in severe range ≥ 24 | | 6 months | Intervention | OR 0.6, 95% CI 0.4, 0.9, p=.02
Treatment response
Fortney, 2006 ^131^ | Percent with 50% improvement in SCL-20 | | 6 months | Intervention | NNT=11
12 months | Intervention | NS
Grypma, 2006 ^93^ | Percent with 50% improvement in PHQ-9 | All depression patients | 6 months | | NS | IMPACT intervention group compared to post-study integrated care group.
Patients over 60 years | 6 months | | NS
IMPACT ^2,^ ^179^ | Percent with 50% improvement in SCL-20 | | 3 months | Intervention | 2.73, 95% CI 2.10; 3.54, p<.001
IMPACT ^2,^ ^179^ | Percent with 50% improvement in SCL-20 | | 6 months | Intervention | 2.21, 95% CI 1.76; 2.76, p<.001
IMPACT ^2,^ ^179^ | Percent with 50% improvement in SCL-20 | | 12 months | Intervention | 26.85, 95% CI 22.34; 31.35, p<.0001
IMPACT ^2,^ ^179^ | Percent with 50% improvement in SCL-20 | | 18 months | Intervention | 16.99, 95% CI 12.34; 21.64, p<.0001
24 months | Intervention | 10.87, 95% CI 6.16; 15.57, p<.0001
Pathways ^12^ | Percent with 50% improvement in SCL-90 | | 6 months | | NS
12 months | | NS
PROSPECT ^125,^ ^127^ | Percent with 50% improvement in HRSD | All patients | 4 months | | OR 2.7, 95% CI 1.5; 4.9, p=.001 | At 8 months, patients taking medication only showed more improvement than patients with IPT only, P=.02
PROSPECT ^125,^ ^127^ | Percent with 50% improvement in HRSD | All patients | 8 months | | OR 2.1, 95% CI 1.1; 3.8, p=.02 | At 8 months, patients taking medication only showed more improvement than patients with IPT only, P=.02
PROSPECT ^125,^ ^127^ | Percent with 50% improvement in HRSD | 12 months | | OR 2.0, 95% CI 1.1; 3.8 P=.02
PROSPECT ^125,^ ^127^ | Percent with 50% improvement in HRSD | Major depression | 4 months | | OR 3.9, 95% CI 1.8; 8.5, p<.001
PROSPECT ^125,^ ^127^ | Percent with 50% improvement in HRSD | Major depression | 8 months | | OR 3.0, 95% CI 1.4; 6.4 P=.006
PROSPECT ^125,^ ^127^ | Percent with 50% improvement in HRSD | 12 months | | NS
PROSPECT ^125,^ ^127^ | Percent with 50% improvement in HRSD | Clinically significant minor depression | 4 months | | NS
PROSPECT ^125,^ ^127^ | Percent with 50% improvement in HRSD | Clinically significant minor depression | 8 months | | NS
12 months | | NS
RESPECT-D ^120^ | Percent with 50% improvement in SCL-20 | | 3 months | Intervention | OR 2.2, 95% CI 1.4; 3.4, p=.001
6 months | Intervention | OR 1.7, 95% CI 1.1; 2.7, p=.021
Simon, 2004 ^84^ | Percent with 50% improvement in SCL-20 | Telephone psychotherapy plus care management | 6 months | Intervention | NNT=6.4 | Usual care as comparison.
Telephone care management | 6 months | Intervention | NS | Usual care as comparison
Finley, 2003 ^108^ | Percent with 50% improvement in brief inventory for depressive symptoms | | 6 months | | NS
Datto, 2003 ^97^ | Percent with 50% improvement in CES-D | | 16 weeks | | NS
Hedrick, 2003 ^87^ | Percent with 50% improvement in SCL-20 | | 3 months | | NS
9 months | | NS
Tutty, 2000 ^89^ | Percent with 50% improvement in SCL-20 | | 3 months | | NS
6 months | | NS
Katon, 1995 ^102^ | Percent with 50% improvement in SCL-20 | Minor depression | | | NS
Katon, 1995 ^102^ | Major depression | 7 months | Intervention | P<.005 | Post hoc analysis showed improvement accrued to patients who required a medication adjustment
Katon, 1995 ^102^ | Percent with 50% improvement in Inventory of depressive symptomatology (clinician rated) | Minor depression | | | NS
Major depression | 7 months | Intervention | P<.02 | Post hoc analysis showed improvement accrued to patients who required a medication adjustment.
Katon, 1996 ^88^ | Percent with 50% improvement in SCL-20 | Major depression | 4 months | Intervention | P=.002 | Group × time trend
Katon, 1996 ^88^ | Percent with 50% improvement in SCL-20 | 7 months | Intervention | P=.04 | Group × time trend
Katon, 1996 ^88^ | Percent with 50% improvement in SCL-20 | Minor depression | 4 months | | NS
7 months | | NS
Hunkeler, 2000 ^110^ (reporting telehealth nurse only, not peer support) | Percent with 50% improvement in Hamilton depression rating score | | 6 weeks | Intervention | P=.01
Hunkeler, 2000 ^110^ (reporting telehealth nurse only, not peer support) | 6 months | Intervention | P=.003
Hunkeler, 2000 ^110^ (reporting telehealth nurse only, not peer support) | Percent with 50% improvement in Beck depression rating score | | 6 weeks | | NS
6 months | | P=.05
Simon, 2000 ^99^ | Percent with 50% improvement in SCL-20 | Care management arm | 6 months | Intervention | OR 2.22, 95% CI 1.31; 3.75
Katzelnick, 2000 ^100^ | Percent with 50% improvement in Hamilton depression score | | 12 months | Intervention | P<.001 | 53.2% compared to 32.8%
Remission
Fortney, 2006 ^131^ | Percent with SCL-20 <0.5 | | 6 months | Intervention | NS
12 months | Intervention | NNT=11
IMPACT ^2,^ ^121^ | Percent with SCL-20 <0.5 | | 3 months | Intervention | 3.63, 95% CI 2.46; 5.38, p<.001
IMPACT ^2,^ ^121^ | Percent with SCL-20 <0.5 | | 6 months | Intervention | 2.16, 95% CI 1.69; 2.76, p<.001
IMPACT ^2,^ ^121^ | Percent with SCL-20 <0.5 | | 12 months | Intervention | 17.48, 95% CI 13.78; 21.18, p<.0001
IMPACT ^2,^ ^121^ | Percent with SCL-20 <0.5 | | 18 months | Intervention | 9.31, 95% CI 5.77; 12.85, p<.0001
IMPACT ^2,^ ^121^ | 24 months | Intervention | 5.65, 95% CI 2.12; 9.17, p=.0018
Percent with SCID ≤1 | | 6 months | Intervention | OR 0.50, 95% CI 0.40; 0.62, P<.001
PROSPECT ^125,^ ^127^ | Percent with HRSD <10 | All patients | 4 months | | OR 3.7, 95% CI 1.7; 7.7, p=<.001 | Treatment × time p<.01 for medication only, vs. IPT only
PROSPECT ^125,^ ^127^ | Percent with HRSD <10 | All patients | 8 months | | NS | Treatment × time p<.01 for medication only, vs. IPT only
PROSPECT ^125,^ ^127^ | Percent with HRSD <10 | 12 months | | NS
PROSPECT ^125,^ ^127^ | Percent with HRSD <10 | Major depression | 4 months | | OR 6.7, 95% CI 2.5; 17.9, p<.001
PROSPECT ^125,^ ^127^ | Percent with HRSD <10 | Major depression | 8 months | | NS
PROSPECT ^125,^ ^127^ | Percent with HRSD <10 | 12 months | | NS
PROSPECT ^125,^ ^127^ | Percent with HRSD <10 | Clinically significant minor depression | 4 months | | NS
PROSPECT ^125,^ ^127^ | Percent with HRSD <10 | Clinically significant minor depression | 8 months | | NS
PROSPECT ^125,^ ^127^ | 12 months | | NS
PROSPECT ^125,^ ^127^ | Percent with HRSD <7 | All patients | 4 months | | OR 2.0, 95% CI 1.0; 3.8, p=.04
PROSPECT ^125,^ ^127^ | Percent with HRSD <7 | All patients | 8 months | | OR 2.1, 95% CI 1.1; 4.2, p=.02
PROSPECT ^125,^ ^127^ | Percent with HRSD <7 | 12 months | | NS
PROSPECT ^125,^ ^127^ | Percent with HRSD <7 | Major depression | 4 months | | OR 3.6, 95% CI 1.4; 9.4, p=.007
PROSPECT ^125,^ ^127^ | Percent with HRSD <7 | Major depression | 8 months | | OR 3.2, 95% CI 1.3; 7.9, p=.01
PROSPECT ^125,^ ^127^ | Percent with HRSD <7 | 12 months | | NS
PROSPECT ^125,^ ^127^ | Percent with HRSD <7 | Clinically significant minor depression | 4 months | | NS
PROSPECT ^125,^ ^127^ | Percent with HRSD <7 | Clinically significant minor depression | 8 months | | NS
12 months | | NS
RESPECT-D ^120^ | Percent with SCL-20 <0.5 | | 3 months | Intervention | OR 2.1, 95% CI 1.2; 3.7, p=.018
6 months | Intervention | OR 1.9, 95% CI 1.2; 3.3, p=.014
Finley, 2003 ^108^ | Percent with brief inventory for depressive symptoms <9 | | 6 months | | NS
Partners in Care ^122,^ ^123^ | Percent with modified CES-D <20 | | 6 months | All interventions | P=.005
Partners in Care ^122,^ ^123^ | 12 months | All interventions | P=.04
Percent without clinical diagnosis, based on full 12-month CIDI | | 2 years | QI-therapy, vs. QI-meds | P=.04
Datto, 2003 ^97^ | Percent below CES-D=16 (low level symptoms) | | 16 weeks | Intervention | OR 6.58, 95% CI 1.57; 27.03, p=.01
Percent below CES-D=11 | | 16 weeks | | NS
Hedrick, 2003 ^87^ | Percent with SCL-20 ≥1.75 | | 3 months | | NS | Collaborative care patients with baseline scores above 1.75 were significantly less likely to be above 1.75 at 3 months.
9 months | | NS
Boudreau, 2002 ^175^ | Percent with major depression as measured with SCID | | 12 months | | NS
Tutty, 2000 ^89^ | Percent with SCID ≤1 | | 3 months | | NS
6 months | | NS
Katon, 1999 ^103^ (4 sites, N=228) | Percent with SCID ≤1 | | 3 months | Intervention | P=.01
6 months | Intervention | P=.05
QuEST) ^5^ | Percent below CES-D=16 | | 24 months | Intervention | P<.02 | Treatment × time
Katzelnick, 2000 ^100^ | Percent below Hamilton depression score<7 | | 12 months | Intervention | P<.001 | 27.7% compared to 12.8%
Medical
IMPACT ^128,^ ^129^ | Arthritis pain intensity | | 3 months | Intervention | -0.58, 95% CI -0.9; -0.25, p<.001
IMPACT ^128,^ ^129^ | Arthritis pain intensity | | 6 months | | NS
IMPACT ^128,^ ^129^ | 12 months | Intervention | -0.53, 95% CI-0.92; -0.14, p=.009
IMPACT ^128,^ ^129^ | Arthritis interferes with daily activities | | 3 months | Intervention | -0.67, 95% CI -1.06; -0.27, p=.001
IMPACT ^128,^ ^129^ | Arthritis interferes with daily activities | | 6 months | Intervention | -0.56, 95% CI-0.96; -0.16, p=.006
IMPACT ^128,^ ^129^ | 12 months | Intervention | -0.59, 95% CI -1; -0.19, p=.004
IMPACT ^128,^ ^129^ | Arthritis pain interferes with daily activities | | 3 months | Intervention | -0.24, 95% CI -0.39; -0.09, p=.002
IMPACT ^128,^ ^129^ | Arthritis pain interferes with daily activities | | 6 months | Intervention | -0.22, 95% CI-0.36; -0.09, p=.005
IMPACT ^128,^ ^129^ | 12 months | Intervention | -0.26, 95% CI -0.41; -0.10, p=.002
IMPACT ^128,^ ^129^ | Graded chronic pain scale for arthritis pain severity | | 12 months | Intervention | Beta 0.15 (SE 0.06), p=.026 | Interaction: intervention × pain severity
IMPACT ^128,^ ^129^ | 12 months | | NS | Interaction: intervention × pain activity interference
IMPACT ^128,^ ^129^ | Graded chronic pain scale for arthritis pain activity interference | | 12 months | Intervention | Beta 0.14 (SE 0.07), p=.04 | Interaction: intervention × pain severity
12 months | | Beta 0.13 (SE 35), p=.015 | Interaction: intervention × pain activity interference
Pathways ^113^ | HbA1c level | | 6 months | | NS
12 months | | NS
ANXIETY DISORDERS
Panic symptoms
Roy-Byrne, 2001 ^109^ | PDSS Panic disorder severity scale | | 3 months | | NS | Intervention × time p=.05, driven by reduction in anticipatory anxiety
Roy-Byrne, 2001 ^109^ | PDSS Panic disorder severity scale | | 6 months | Intervention | P=.003 | Intervention × time p=.05, driven by reduction in anticipatory anxiety
Roy-Byrne, 2001 ^109^ | PDSS Panic disorder severity scale | | 9 months | | NS | Intervention × time p=.05, driven by reduction in anticipatory anxiety
12 months | | NS
Rollman, 2005 ^101^ | PDSS Panic Disorder Severity Scale | All patients | 12 months | Intervention | 0.33, 95% CI 0.04; 0.62, p=.02 | Intervention × time
Panic disorder | 12 months | Intervention | 0.57, 95% CI 0.18; 0.96, p=.003 | Intervention × time
Anxiety symptoms
Roy-Byrne, 2001 ^109^ | Anxiety sensitivity scale | | 3 months | Intervention | P=.002 | Intervention × time p=.018
Roy-Byrne, 2001 ^109^ | Anxiety sensitivity scale | | 6 months | Intervention | P<.001 | Intervention × time p=.018
Roy-Byrne, 2001 ^109^ | Anxiety sensitivity scale | | 9 months | | NS | Intervention × time p=.018
12 months | Intervention | P=.035
| Panic related agoraphobic avoidance | | 12 months | | NS
CCAP ^9^ | Anxiety sensitivity index score | | 3 months | Intervention | Effect size 0.44
CCAP ^9^ | Anxiety sensitivity index score | | 6 months | Intervention | Effect size 0.45
CCAP ^9^ | Anxiety sensitivity index score | | 9 months | Intervention | Effect size 0.44
12 months | Intervention | Effect size 0.43
Rollman, 2005 ^101^ | * SIGH-A Hamilton anxiety rating scale | All patients | 12 months | Intervention | 0.38, 95% CI 0.09; 0.67, p=.03 | Intervention × time,
General anxiety disorder | 12 months | | NS
Fear symptoms
Roy-Byrne, 2001 ^109^ | Fear questionnaire agoraphobic subscale | | 12 months | | NS
Depression symptoms
Roy-Byrne, 2001 ^109^ | Mean CES-D | | 3 months | Intervention | P=.002 | Intervention × time p=.03
Roy-Byrne, 2001 ^109^ | Mean CES-D | | 6 months | Intervention | P=.005
Roy-Byrne, 2001 ^109^ | Mean CES-D | | 9 months | Intervention | P=.036
12 months | Intervention | P=.02
CCAP ^9^ | Mean CES-D | | 3 months | Intervention | Effect size 0.29
CCAP ^9^ | Mean CES-D | | 6 months | Intervention | Effect size 0.29
CCAP ^9^ | Mean CES-D | | 9 months | Intervention | Effect size 0.27
12 months | Intervention | Effect size 0.26
Rollman, 2005 ^101^ | Hamilton depression rating scale | All patients | 12 months | Intervention | 0.57, 95% CI 0.25; 0.46, p=.03 | Intervention × time
Price, 2000 ^91^ | Mean Shedler Quick Psycho Diagnostics Panel | | 6 months | Intervention | P=.046
Treatment response
Roy-Byrne, 2001 ^109^ | 40% reduction in PDSS | | 3 months | | NS
Roy-Byrne, 2001 ^109^ | 40% reduction in PDSS | | 6 months | Intervention | P=.001
Roy-Byrne, 2001 ^109^ | 40% reduction in PDSS | | 9 months | | NS
12 months | Intervention | P=.048
Rollman, 2005 ^101^ | 40% reduction in SIGH-A | All patients | 12 months | Intervention | 30.8, 95% CI 17.0; 44.7, p<.001
Rollman, 2005 ^101^ | General anxiety disorder | 12 months | | NS
Rollman, 2005 ^101^ | 40% reduction in PDSS | All patients | 12 months | Intervention | 20.7, 95% CI 9.7; 31.5, p<.001
Rollman, 2005 ^101^ | Panic disorder | 12 months | Intervention | 32.2, 95% CI 15.5; 48.9, p<.001
40% reduction in Hamilton depression rating | All patients | 12 months | Intervention | 28.5, 95% CI 15; 42.6, p<.001
Remission
Roy-Byrne, 2001 ^109^ | Anxiety sensitivity score <20 | | 3 months | Intervention | P=.004
Roy-Byrne, 2001 ^109^ | Anxiety sensitivity score <20 | | 6 months | Intervention | P=.004
Roy-Byrne, 2001 ^109^ | Anxiety sensitivity score <20 | | 9 months | | NS
12 months | Intervention | P=.005
CCAP ^9^ | Anxiety sensitivity score <20 | | 3 months | Intervention | Effect size 0.40
CCAP ^9^ | Anxiety sensitivity score <20 | | 6 months | Intervention | Effect size 0.48
CCAP ^9^ | Anxiety sensitivity score <20 | | 9 months | Intervention | Effect size 0.47
CCAP ^9^ | 12 months | Intervention | Effect size 0.51
CCAP ^9^ | High end-state functioning | | 3 months | Intervention | Effect size 0.23
CCAP ^9^ | High end-state functioning | | 6 months | Intervention | Effect size 0.29
CCAP ^9^ | High end-state functioning | | 9 months | Intervention | Effect size 0.32
12 months | Intervention | Effect size 0.34
Price, 2000 ^91^ | Shedler quick diagnostics panel <10 | | 6 months | Intervention | P=.025 | 55.6% intervention vs. 22.8% control achieved remission
OTHER DISORDERS
Somatization symptoms
Katon, 1992 ^107^ | Mean SCL somatization | | 6 months | | NS
12 months | | NS
Depression symptoms
Katon, 1992 ^107^ | Mean SCL depression | | 6 months | | NS
12 months | | NS
Anxiety symptoms
Katon, 1992 ^107^ | Mean SCL anxiety | | 6 months | | NS
12 months | | NS
ADHD symptoms
Epstein, 2007 ^112^ | Conners Parent Rating Scale | | 12 months | | NS
Drinking severity
PRISM-E ^126^ | Mean change in number of drinks per week | | 6 months | | NS | In total, 21% reduced drinking; 18% in integrated care, 23% in referral care
Mean change in number of binge episodes | | 6 months | | NS

The PRISM-E authors noted that the frequency of treatment response across all patient populations was closer to treatment-as-usual outcomes in other trials such as IMPACT and PROSPECT. ^118^ Since treatment-as-usual in practice generally involves referral care, it appears that the PRISM-E trial results are consistent with the null finding that increased levels of integration do not demonstrate improved outcomes. The results of this effectiveness study using naturalistic settings highlights the importance of the need to understand what makes a good clinical process: adequate implementation, proper adaptive fit of an intervention to the clinical environment, and an intervention that positively impacts outcomes are all necessary for effectiveness to be achieved.

### Key Question 2: To What Extent does the Impact of Integrated Care Programs on Outcomes Vary for Different Populations?

As seen in the results section for Key Question 1, while integration levels were not shown to be related to improved outcomes, the integration programs tested improved outcomes nonetheless. While the companion articles are not extensive, there are some subgroups of interest by which outcomes can be examined with a narrative format. The next three sections take a look at outcomes by illness category, patient age, and population differences by social factors, comorbidity, and individual differences

Illness categories. Depression disorder research has by far the most mature literature, with the largest body of evidence and a few trials reporting long-term results of more than 12 months, ^2^ – ^5^ one of five years. ^6^ Anxiety disorder research is still in the process of establishing baseline evidence of efficacy and has not yet taken the research to more naturalistic effectiveness studies, although the larger-scale CALM study ^7^ currently in the field is moving in that direction. Other disorders minimally addressed in the literature include somatization, at-risk alcohol use, and ADHD. Limiting the review to programs in the United States has precluded use of the considerable somatization research available from several European nations, particularly Germany and Denmark.

Unfortunately, while there is some literature on using chronic care models for treating alcohol use disorders in primary care settings, ^119^ very little is available for alcohol abuse behavioral programs, in part because studies often used larger substance abuse populations and did not report results separately for alcohol subgroups. Research on the efficacy of brief interventions or pharmaceutical treatments were not included in the review if the interventions examined a single treatment facet that might be incorporated into an integrated program, a scope limitation that was discussed in the methods section.

Table 10 presents clinical outcomes by mental illness condition. Effects for symptom severity consistently favor integrated care for depression ^2,^ ^3,^ ^84,^ ^87,^ ^89,^ ^103,^ ^110,^ ^113,^ ^118,^ ^120^ – ^125^ and anxiety ^9,^ ^91,^ ^101,^ ^109^ but were nonsignificant for somatization as measured by somatization, depression, and anxiety symptoms, ^107^ at-risk alcohol drinking as measured by change in drinking behavior, ^126^ and ADHD. ^112^ Anxiety disorder research includes more varied measures of symptom severity, which can include symptoms of panic, anxiety sensitivity, fear, and depression. Treatment response and remission rate outcomes are seen in both depression and anxiety research and exhibit the same consistently favorable outcomes for integrated care for depression ^2,^ ^5,^ ^84,^ ^92,^ ^97,^ ^102,^ ^103,^ ^110,^ ^120^ – ^123,^ ^125,^ ^127^ and anxiety, ^9,^ ^91,^ ^101,^ ^109^ when significant.

Effects of integrated care effects may not be immediately apparent in improvements in outcomes depression. ^110,^ ^118^ More commonly though, the results show a weakening effect over time, particularly within the first 6 to 12 months. ^2,^ ^3,^ ^87,^ ^92,^ ^103,^ ^120^ – ^123,^ ^125,^ ^127^ Anxiety disorder research demonstrates the same patterns. ^9,^ ^101,^ ^109^

Effects for minor depression or clinically significant depression symptoms are not as clear as for major depression. Three trials that specifically examined outcomes by level of depression found improvements for patients with major depression but not minor depression. ^3,^ ^88,^ ^102,^ ^103,^ ^125^ Trials for other mental health disorders did not address severity.

Only depression research has examined the possibility of improved medical condition outcomes as a result of integrated care. The research has documented improvements in arthritis pain ^128,^ ^129^ but not HbA1c levels for diabetic patients with depression. ^113^

Another major category of outcomes examined in integrated care research is functional impairment and quality of life outcomes, which are presented in Table 13, by mental illness condition. Functioning and disability are variously measured using SF12 overall functional impairment and role limitations, IADLs, work productivity and absenteeism, the Work and Social Disability scale, the Sheehan disability scale, the WHO disability scale, and SF36 social functioning. Again, the positive effects consistently favored integrated care for both depression ^2,^ ^3,^ ^5,^ ^87,^ ^121,^ ^122,^ ^130^ and anxiety. ^9,^ ^109^ The depression studies generally examined time trends beyond one year, while the anxiety study durations were limited to one year or less. Given the variability in the measures and the more limited reporting, the evidence is less robust in this area.

Table 13 Financial/economic outcomes

Study, Project Name or Author | Program Costs per Patient | Cost Savings | Cost/Unit of Benefit | Interval | Other Costs, Comments, and Notes
Depression
Unutzer, 2002 ^121^ IMPACT | Costs of intervention program $553 | N/A | | 12 months | All care managers and team psychiatrists free of charge to patient
Katon, 2005 ^185^ IMPACT | Average cost of the intervention program $591 Total outpatient cost $295 (95% CI -525; 1115) higher for intervention | N/A | Total incremental outpatient cost per depression-free day $2.76 (95% CI -4.95; 10.47) Cost per QALY $2,519–$5,037 | 24 months | Potential cost-offset in non-mental health related ambulatory care. 25% probability that the IMPACT intervention had lower costs and greater effectiveness. Best results for double depression.
Katon, 2002 ^186^ IMPACT diabetes subgroup (N=418) | Average cost of the intervention program $597 Total outpatient costs $25 (95% CI -1,638; 1572) higher for intervention; | Total cost savings $896 | Cost per QALY range $198–$397; Incremental outpatient cost per depression-free day 25 cents (-$14; $15) Incremental net benefit $1129 (692; 1572) | 24 months | Potential cost-offset in non-mental health related ambulatory care. Probability that the intervention improved outcomes and saved money was 67.3%
Unutzer, 2008 ^187^ IMPACT N=551 | | Estimated total healthcare cost savings of $3,363 | | 48 months | 87% probability that the intervention had lower healthcare costs. Figures from 2 participating HMOs.
Simon, 2007 ^188^ Pathways | Average cost of intervention program $545 plus $27 screening cost | Total cost savings $314 | Incremental outpatient costs per depression-free day -$5.2 (95% CI -17.6 to 7.2) | 24 months | Greatest benefit accrued to patients who had not previously used antidepressants
Liu, 2003 ^189^ Hedrick, 2003 ^87^ | Average cost of intervention program $237 Total outpatient costs $519 | N/A | Incremental program cost per depression-free day $24 (95% CI -105; 148) Incremental outpatient cost per depression-free day $33 (95% CI -106; 232) | 9 months
Simon, 2001 ^190^ Katon, 1999 ^103^ | Average incremental cost of depression treatment in the program $357 | N/A | Incremental program cost per depression-free day $21.44 (95% CI 7.56; 125.76) | 6 months | Over 28 months, nonsignificant trends in total depression costs and total outpatient costs; nonsignificant ambulatory costs between intervention and active control
VonKorff, 1998 ^191^ Katon, 1995 ^102^ | Average incremental cost of major depression treatment cost $487; minor depression treatment cost $641 | N/A | Incremental cost per successfully treated case major depression $1592, minor depression -$8190 (many successfully treated in usual care) | 12 months | Psychiatrist model Specialty MH services costs lower in collaborative care ($123) vs. usual care ($317) for major depression. No cost-offset noted for minor depression.
VonKorff, 1998 ^191^ Katon, 1996 ^88^ | Average incremental cost of major depression treatment cost $264; minor depression treatment cost $520 | N/A | Incremental cost per successfully treated case major depression $940 minor depression $1567 | 12 months | Brief CBT model Specialty MH services costs lower in collaborative care ($123) vs. usual care ($317) for major depression. No cost-offset noted for minor depression.
Simon, 2002 ^192^ Katon, 2001 ^98^ | Incremental cost for depression treatment $273 | | Incremental outpatient cost effectiveness per depression-free day $14 (95% CI -35; 248) | 12 months
Simon, 2001 ^193^ Katzelnick, 2000 ^100^ | | N/A | Incremental outpatient cost effectiveness per depression-free day $21.12 (95% CI 10.53; 37.61) Incremental total health care costs plus time in treatment per depression-free day $51.84 (95% CI 17.37; 108.47) | 12 months | Depression treatment in high utilizers was associated with improved clinical outcomes at higher health service costs
Tutty, 2004 ^89^ | Overall program cost per patient $153, $26 per session; | N/A | | 6 months
Simon, 2000 ^99^ | (Average incremental costs $22 feedback only, $83 for care management) | | | 6 months
Wells, 2000 ^123^ Partners in care | (Intervention and time costs for participation $30,000 to $72,000) | N/A | | 12 months | QI-therapy, organizations reduced therapy co-pay to the level of a primary care visit co-pay, $0 to $10, instead of usual $20 to $30
Schoenbaum, 2001 ^132^ Partners in Care | Average health care costs increased $419 in QI-meds and $485 in QI-therapy | N/A | Costs per QALY range $15,331 to $36,467 for QI-meds and $9,478 to $21,478 for QI-therapy | 24 month | Patients also employed more days during the study period.
Rost, 2001 ^124^ QuEST | ($12 in administrative staff time to identify cases; $61 to deliver the intervention to each patient) | N/A | | 6 months | $4,661 per enhanced care practice on administrative staff
Pyne, 2003 ^194^ QuEST | Average incremental cost of program $634 | N/A | Incremental cost-effectiveness per QALY range $11,341 to $19,976 | 12 months
Pyne, 2005 ^195^ QuEST N=200 | Incremental total cost for patients receptive to antidepressant medication $516, $474 for nonreceptive | N/A | Incremental cost effectiveness per QALY range $5,864 to $14,689 for patients receptive to antidepressants; negative for nonreceptive | 12 months | Receptive to both medication and counseling total cost $683. Receptive to either medication or counseling total cost $668.
Dickinson, 2005 ^196^ QuEST | | Outpatient cost savings $980 for psychological complaint patients | | 24 months | Outpatient cost increase $1378 for enhanced of physical complaints patients
Rost, 2005 ^197^ QuEST | | Incremental health plan costs decreased $568. | Incremental cost effectiveness per QALY range $9,592 to $14,306 | 24 months | Health plan medication costs increased by $325 more than usual care; patient time and transportation costs increased $701
Oxman, 2002 ^96^ RESPECT-D | Estimated $150 per patient (during acute phase.)
Anxiety Disorder
Katon, 2002 ^134^ CCAP | Total incremental out-patient costs $492 higher in intervention | Total ambulatory and in-patient cost $276 savings | Cost saving $4 per anxiety-free day. Cost per QALY range $14,158 to $24,776. Total incremental cost-effectiveness per anxiety-free day $8.40 (95% CI 2.80; 14.0) | 12 months | The combined CBT and pharmacotherapy intervention was associated with a robust clinical improvement compared to usual care, with a moderate increase in ambulatory costs
Katon, 2002 ^133^ Roy-Byrne, 2001 ^109^ | Total incremental cost of the intervention $205 | Total outpatient cost saving $325 | Incremental ambulatory cost-effectiveness per anxiety-free day -$4 (-$23 to $14) | 12 months | 0.70 probability the intervention is lower in costs with greater effectiveness

Physical and mental quality of life measures were also examined by depression and anxiety studies. Most commonly used were the SF12 physical and mental component scales. However, far fewer studies employed these outcome measures. Of those that did, only IMPACT found positive improvements in the SF12-PCS due to integrated care, ^2,^ ^130^ and the anxiety trials were nonsignificant. ^9,^ ^101^ Mental quality of life faired only slightly better, with consistently, if infrequently, positive improvements associated with integrated care for depression ^83,^ ^110,^ ^122,^ ^123,^ ^131^ and anxiety. ^9,^ ^101^

Table 14 presents information on select process of care measures including adherence/adequate dosage and patient satisfaction with treatment. The concepts are measured in a variety of ways, making it difficult to create summary measures. Overall, though, when significant, the results again consistently favor interventions for all mental illnesses. Even with the interventions, however, adherence numbers still show room for improvement. For example Adler and colleagues ^106^ report that at the highest only 61 percent of intervention patients were adherent, with the greatest benefit for naïve patients who were new to antidepressant use. One of the highest rates of use was reported for a VA study ^87^ with 80 percent of intervention patients receiving antidepressants at nine months. Anxiety disorders were less likely to show significant findings for adherence. Satisfaction with integrated care was, perhaps not surprisingly, significant for integrated care patients when reported. There was no difference of note between depression and anxiety disorder integrated care programs.

Table 14 Integrated care trials by target patient age

Project Name or Author, Year | Pediatric | Adult | Geriatric
Depression Disorders
Fortney, 2006 ^92^ | | X
Grypma, 2006 ^93^ | | X
IMPACT ^2,^ ^94,^ ^121,^ ^130,^ ^173^ | | | X
Clarke, 2005 ^83^ | X (adolescent)
PROSPECT ^95,^ ^125,^ ^135^ | | | X
Pathways ^69,^ ^113^ | | X
Partners In Care ^86,^ ^122,^ ^123,^ ^136,^ ^176^ | | X
Hedrick, 2003 ^87^ | | X
PRISM-E ^82,^ ^118,^ ^198^ | | | X
Katon, 1996 ^88^ | | X
Katon, 2001 ^98^ | | X
PRISM-E ^82,^ ^118,^ ^198^ | | | X
RESPECT-D ^96,^ ^120^ | | X
Simon, 2004 ^84^ | | X
Adler, 2004 ^106^ | | X
Swindle, 2003 ^85^ | | X
Datto, 2003 ^97^ | | X
Boudreau, 2002 ^104,^ ^175^ | | X
Tutty, 2000 ^89^ | | X
QuEST ^5,^ ^111,^ ^124^ | | X
Hilty, 2007 ^105^ | | X
Katzelnick, 2000 ^100^ | | X
Finley, 2003 ^108^ | | X
Katon, 1995 ^102^ | | X
Katon, 1999 ^103^ | | X
Hunkeler, 2000 ^110^ | | X
Simon, 2000 ^99^ | | X
Asarnow, 2005 ^114^ | X (adolescent)
Anxiety Disorders
Roy-Byrne, 2001 ^109^ | | X
CCAP ^9,^ ^139^ | | X
Rollman, 2005 ^101,^ ^177^ | | X
Price, 2000 ^91^ | | X
Other Disorders
Katon, 1992 ^107^ | | X
Epstein, 2007 ^112^ | X (1^st^ through 5^th^ grade)
PRISM-E (at risk alcohol) ^82,^ ^126,^ ^198^ | | | X

Table 15 summarizes the information provided on the cost implications of several studies. None did a formal business case analysis. Indeed, the business case varies with the perspective. From a societal perspective, we may be interested in traditional cost effectiveness (CE) measures such as the cost per QALY (quality-adjusted life year). The IMPACT studies show several CE calculations that suggest the added treatment costs are modest in light of the benefits. A few other studies show higher costs per QALY ^132^ but are still well below the typical thresholds.

Table 15 Patient subgroup/comorbidity concerns

Outcome Project Name or Author | Measurement | Patient Category | Comment
DEPRESSION DISORDERS
Social Factors
IMPACT, 2007 ^199^ | Process of care: use of antidepressants, psychotherapy, or any depression treatment. Mean SCL-20. SF-12 General health and PCS-12. Satisfaction with care. | Preplanned contrasts between poor older depressed adults living at or below 30% of median income and older adults living above 30% | Poor in intervention group had generally worse scores than not poor and lower program utilization. Poor showed significant improvement in depression symptoms, and general health. Improvement in physical quality of life showed by 12 months.
IMPACT, 2007 ^199^ | Process of care: use of antidepressants, psychotherapy, or any depression treatment. Mean SCL-20. SF-12 General health and PCS-12. Satisfaction with care. | Poor N=576
Not Poor N=1,225
IMPACT, 2005 ^137^ | Process of care: use of antidepressants, psychotherapy, or any depression treatment. Mean SCL-20, treatment response and remission rates. SF-12 Overall functional impairment. Satisfaction with care. | Minority versus non-minority elderly depression patients | No significant interactions were found between intervention and ethnic groups in clinical outcomes, functioning, and process of care. Blacks had the largest intervention vs. control differences in depression score. Latinos showed largest impact of intervention on processes of care.
IMPACT, 2005 ^137^ | Process of care: use of antidepressants, psychotherapy, or any depression treatment. Mean SCL-20, treatment response and remission rates. SF-12 Overall functional impairment. Satisfaction with care. | Non-minority N=1,388
Minority N=360
Partners in Care, 2004 ^6^ | Probable depression diagnosis, SF12 MCS | Minority versus non-minority depression patients | QI-Therapy improved probable disorder and mental health quality of life at 5 years for Latino and African Americans but not Whites.
Total N=924, not reported by group
Asarnow, 2005 ^114^ | | | Although numbers were not reported by minority status, patient population was 56% Hispanic/Latino and 13% white. Significant findings for the intervention in this case support effectiveness at minimum for Latino adolescents
Comorbidity Factors
IMPACT, 2007 ^8^ | Treatment response: 50% improvement in SCL-20 | No/low pain versus high pain patient populations | Pain was significantly associated with lower treatment response to collaborative care, including arthritis pain.
IMPACT, 2007 ^8^ | Treatment response: 50% improvement in SCL-20 | No/low pain N=1,163 | Pain was significantly associated with lower treatment response to collaborative care, including arthritis pain.
High pain N=1,640
IMPACT, 2006 ^128^ | Graded chronic pain scale for arthritis pain severity | Low versus high pain patient populations | The effect size of the intervention on pain intensity was more than 8 times greater for patients with lower baseline pain severity.
IMPACT, 2006 ^128^ | Graded chronic pain scale for arthritis pain severity | Intervention group N=506 | The effect size of the intervention on pain intensity was more than 8 times greater for patients with lower baseline pain severity.
Usual care group N=495
Rost, 2007 ^200^ | Hospitalization rates | Rural versus urban, patients from both QuEST and Partners in Care studies. | Rural patients with depression were hospitalized significantly more frequently than urban patients, controlling for group assignment.
Rost, 2007 ^200^ | Hospitalization rates | Rural N=304 | Rural patients with depression were hospitalized significantly more frequently than urban patients, controlling for group assignment.
Urban N=1,151
QuEST, 2006 ^138^ | SF-12 MCS across time | Rural versus urban depression patients | Intervention did not improve mental health status for rural depression patients. Intervention showed a strong impact on urban depression patients.
QuEST, 2006 ^138^ | SF-12 MCS across time | Rural N=160 | Intervention did not improve mental health status for rural depression patients. Intervention showed a strong impact on urban depression patients.
Urban N=319
PRISM-E, 2007 ^141^ | Mean CES-D score | Pain severity, interference with work, and type of depression diagnosis | Patients with higher pain severity or pain interference showed less improvement in depression symptoms, primarily driven by patients with major depression. For major depression, pain interference mediated pain severity over time on depression symptoms.
PRISM-E, 2007 ^141^ | Mean CES-D score | Integrated care N=275
Referral care N=249
IMPACT, 2005 ^10^ | Mean SCL-20, overall quality of life, SF-12 MCS | Patients with high comorbid medical illness versus patients with low comorbid illness | Presence of multiple comorbid medical illnesses did not affect patient response to the intervention.
IMPACT, 2005 ^10^ | Mean SCL-20, overall quality of life, SF-12 MCS | Intervention group N=906 | Presence of multiple comorbid medical illnesses did not affect patient response to the intervention.
Usual care group N=895
PROSPECT, 2005 ^11^ | Remission and treatment response | Elderly patients with major depression and specified comorbid medical conditions versus patients without such impairments | Remission and response rates differed for atrial fibrillation and chronic pulmonary disease patients receiving usual care but not intervention care. Infer that an association between medical comorbidity and treatment outcomes for major depression is determined by intensity of depression treatment.
Total N=324
IMPACT, 2004 ^142^ | Depression, functional impairment, diabetes self-care behaviors | Patients with diabetes | Intervention patients showed improvement in depression scores and overall functioning. Weekly exercise increased, but other self-care behaviors were not different between intervention and control. No differences found in Hb1Ac levels, which were relatively low at baseline.
IMPACT, 2004 ^142^ | Depression, functional impairment, diabetes self-care behaviors | Diabetes subgroup N=417
Other N=1,384
Pathways, 2006 ^12^ | Mean SCL-20 score | Diabetes patients with 2+ complications versus uncomplicated diabetes patients | Patients with 2+ complications showed significant improvements in depression scores versus patients with less, who showed effects similar to control group.
Pathways, 2006 ^12^ | Mean SCL-20 score | 0 to 1 complications N=192 | Patients with 2+ complications showed significant improvements in depression scores versus patients with less, who showed effects similar to control group.
2+ complications N=137
PROSPECT, 2007 ^140^ | Remission and treatment response | Elderly depression patients with cognitive impairments versus patients without such impairments | Intervention improved depression response and remission rates regardless of cognitive impairments. Possible evidence that patients with lowest response inhibition may have had delayed responses to the intervention.
Total N=599
IMPACT, 2005 ^139^ | Mean SCL-20 score and treatment response | Depression patients with and without comorbid PTSD and other anxiety disorders | Patients with PTSD showed a delayed response to intervention treatment, but were not significantly different from other intervention patients by 12 months.
IMPACT, 2005 ^139^ | Mean SCL-20 score and treatment response | Depression patient without comorbid PTSD N=1,610 | Patients with PTSD showed a delayed response to intervention treatment, but were not significantly different from other intervention patients by 12 months.
IMPACT, 2005 ^139^ | Mean SCL-20 score and treatment response | Depression patients with comorbid PTSD N=191 | Patients with PTSD showed a delayed response to intervention treatment, but were not significantly different from other intervention patients by 12 months.
IMPACT, 2005 ^139^ | Mean SCL-20 score and treatment response | Depression patients with comorbid panic disorder N=262 | Patients with PTSD showed a delayed response to intervention treatment, but were not significantly different from other intervention patients by 12 months.
Depression patients without comorbid panic disorder N=1,539
TEAM, 2006 ^201^ | Quality of well-being scale, self-administered version. SF-12V MCS and PCS | VA Depression patients with and without comorbid anxiety disorders, including PTSD | 69% of patients had at least one comorbid anxiety disorder. Anxiety disorders predicted quality of well-being beyond depression disorder alone. PTSD also predicted differences in PCS.
TEAM, 2006 ^201^ | Quality of well-being scale, self-administered version. SF-12V MCS and PCS | Depression patients with any anxiety comorbidities N=225 | 69% of patients had at least one comorbid anxiety disorder. Anxiety disorders predicted quality of well-being beyond depression disorder alone. PTSD also predicted differences in PCS.
Depression patients without any anxiety comorbidities N=101
Individual Differences Factors
Pathways, 2006 ^143^ | Depression free days | Independent versus interactive relationship styles (based on attachment theory) | Intervention patients with independent relationship style showed significant improvement, while patients with interactive style showed no difference from usual care. Independent style patients received significantly more PST sessions than those with interactive relationship style.
Pathways, 2006 ^143^ | Depression free days | Interactive relationship style N=134
Independent relationship style N=190
PROSPECT, 2005 ^135^ | Remission rate | Hopelessness and other predictors of remission rate | First remission was earlier among intervention group. Physical and emotional functions predicted poor remission rate. Patients experiencing hopelessness more likely to experience remission in intervention group.
Total N=215
Bush, 2004 ^202,^ ^203^ (data from Katon, 1995 and Katon, 1996) | SCL-20 and treatment response | Predictors of patient treatment response | High neuroticism and history or recurrent major depression or dysthymia predicted poor outcomes in general. Age, gender, depression severity, medical and psychiatric comorbidity were not predictive. Patients with higher depression levels may require longer therapy continuation phase.
Bush, 2004 ^202,^ ^203^ (data from Katon, 1995 and Katon, 1996) | SCL-20 and treatment response | Low SCL=149
High SCL=79
Simon, 2004 ^84^ | Benefit of intervention | Predictors of patient response, including depression severity | Post-hoc analysis. Effects varied by depression severity. No apparent intervention effect among those with mild depression. Intervention effects generally similar for moderate or severe symptoms. Effects did not vary by age, sex, race/ethnicity, educational level, or marital status.
Simon, 2004 ^84^ | Benefit of intervention | Telephone care management N=207
Simon, 2004 ^84^ | Benefit of intervention | Telephone care management plus telephone psychotherapy N=198
Usual care N=195
Gender
Partners in Care, 2004 ^13^ | Probable depression, SF-12 MCS, Self-reported work state. Process of care: probable appropriate care, probable unmet need | Male versus female patients | Probable depression did not differ by gender. SF-12 MCS differed by treatment group and gender over time, a 3-way interaction, with women delaying improvement in QI-Therapy, and improving faster in QI-Meds. Men showed opposite patterns. Men reported faster employment results from QI-Therapy, while women did for QI-Meds.
Partners in Care, 2004 ^13^ | Probable depression, SF-12 MCS, Self-reported work state. Process of care: probable appropriate care, probable unmet need | Women N=941
Men N=358
IMPACT, 2006 ^144^ | Receipt of depression care prior to study enrollment | Male versus female elderly patients | Women more likely to have used antidepressants in past 3 months, or received any form of depression care in past 3 months or over their lifetimes. Qualitative interviews with study providers suggested gender differences in how men experience and express depression, traditional masculine values, and the stigma of chronic mental illness.
IMPACT, 2006 ^144^ | Receipt of depression care prior to study enrollment | Women N=1,160
Men N=453
ANXIETY DISORDERS
CCAP, 2005 ^9^ | Anxiety and depression symptoms, disability, receipt of guideline concordant care | Above versus below median for chronic medical illness burden | Severely medically ill did significantly more poorly on clinical and functional outcomes, although they showed improvement over time. Those with higher medical illness level had significantly higher use of guideline-concordant medication.
CCAP, 2005 ^9^ | Anxiety and depression symptoms, disability, receipt of guideline concordant care | Below RxRisk median N=107
Above RxRisk median N=125
Roy-Byrne, 2001 ^204^ | Treatment response | Predictors of panic disorder patient treatment response | Final regression model included, in addition to control condition, unemployment and emergency room visits as predictors of poor response.
Roy-Byrne, 2001 ^204^ | Treatment response | Nonresponders N=42 | Final regression model included, in addition to control condition, unemployment and emergency room visits as predictors of poor response.
Responders N=55
ADHD
Epstein, 2007 ^112^ | Reduction in DSM-IV symptomatology | Medication compliers versus non-compliers in intervention group | Symptom reduction in compliers was significantly lower than in non-compliers.
Epstein, 2007 ^112^ | Reduction in DSM-IV symptomatology | Compliers N=29 | Symptom reduction in compliers was significantly lower than in non-compliers.
Epstein, 2007 ^112^ | Reduction in DSM-IV symptomatology | Non-compliers N=30
Medication compliers versus controls | Symptom reduction in compliers was significantly lower than in control. Compliers were also more likely to receive higher daily dosage, and controls more likely to receive lowest possible daily dosage.
AT RISK ALCOHOL
PRISM-E, 2006 ^145^ | Treatment initiation: attending initial visit | Predictors of patient behavior | Integrated care participants in pre-contemplative and contemplative stage more likely to initiate treatment than similar patients in referral care. Integrated care patients with no history or desire/attempt to cut down on drinking were more likely than referral care or integrated care patients with a history of desire/attempts.

From the perspective of the health plan, the business case is based on whether the added attention reduces the costs of care overall by reducing emergency room and hospital use or return visits for medical problems. Case identification, a major driver for increased costs, is usually not reimbursed. In the fee-for-service sector, increased case finding may generate business, but in the managed care sector case finding adds additional costs Again, the IMPACT studies suggest actual net savings were achieved, but the basis for the calculations is not always clear in the literature.

Anxiety disorder studies may hold more potential for the business case. CE calculations for Roy-Byrne, 2001 ^133^ suggested a strong possibility that integrated care programs for anxiety disorder may be dominant, with an improved outcomes for reduced costs. However, the later study by Roy-Byrne and colleagues did not have as striking of CE results. ^134^

Patient age. Table 16 lists studies by target population age. The body of evidence is mainly divided between adult and elderly populations. The elderly populations have been a focus of integrated care for depression, represented by some of the strongest studies: IMPACT, ^2,^ ^121^ PRISM-E, ^118^ and PROSPECT. ^125^ All of the anxiety trials have been aimed at the general adult population, with no exclusions for the elderly.

Table 16 Barriers to integrating primary care and mental health care

Type of Barrier | Strategy
Financial; - Carved out mental health services; - Consultation between providers not compensated; - Care manager not always eligible for compensation; - No reimbursement for two encounters on same day with different professionals (public funding); - Mental health services carved out of general medical services; - No reimbursement for telephone consultation | - Permitting credentialed primary care physicians to bill carve out managed behavioral health care organization for mental health care ^167^; - Allow PCPs to bill for behavioral health visit, even when it occurs simultaneously with general medical care visit ^167^; - Care manager employed or under contract with health plan; - Intervention paid through quality improvement funding ^96,^ ^86^; - Care managers (behavioral health specialists) employed by health organization ^170^; - Care specialists ‘loaned’ to primary care, but billed to payer from specialty sector ^170^; - Negotiated pricing for care management services ^155^; - Creation of new CPT codes for billing care management services ^155^; - Pay for Performance funds
Organizational Barriers; - Resistance to change; - Staffing: availability of mental health specialists; acceptance of new roles; - Time: balancing competing demands and burden of case identification; - Expertise and comfort dealing with mental health problems; - Privacy concerns: HIPAA | - Identification of leaders to support/promote the integration ^146^; - Training of allied-professionals (physician extenders) to provide mental health services and care management; - Provider education and support; - Telemedicine ^131^

Because IMPACT shows the strongest evidence for integrated care for depression, the benefits of integrated care for the elderly population are present. However, one study extended the IMPACT program to the full adult population and was able to achieve the same improvements. ^93^ Given that both adults and elderly are well represented in the trials, the evidence for integrated care trials is good for both general populations.

Only three studies addressed the pediatric population. Epstein et al. ^112^ nested a test of the effects of collaborative care within an ADHD titration trial. While the study did not find a direct relationship of integrated care to significant improvements in ADHD symptoms, they did find evidence of collaborative care improving physician use of appropriate titration trials to determine optimal therapeutic doses.

Two studies addressed depression care for adolescents. Clarke et al. ^83^ tested integrated care for adolescents with depression in a pediatric HMO population. This study found weak evidence of integrated care in that the adolescents assigned to receive the psychotherapy, and care management provided by the therapist, had reduced use of antidepressant medication but the same level of improvement as those adolescents in the control group. The nonsignificant difference between the control and intervention arms along with reduced adherence for the intervention group suggests that the patients were substituting psychotherapy for antidepressant treatments. Asarnow et al also demonstrated that psychotherapy was generally preferred to medication. ^114^ There was a significant increase in the use of psychotherapy in the integrated care group but no significant difference between intervention and control groups in medication use. This study, however, found stronger evidence for integrated care improving depression symptoms for adolescents.

Population differences by social factors, comorbidity, and individual differences. A limited number of trials addressed other patient population differences in an attempt to further understand when and for whom a particular intervention was effective. Table 16 organizes preplanned and post-hoc analyses and companion articles reporting secondary analysis of data into social factors, comorbidity factors, and individual differences of patients with mental illness.

When contemplating new ways of providing health services, one should at minimum be concerned that new programs do not add to health disparities. Most studies collected baseline data on ethnic subgroups, 21 for depression, ^2,^ ^83^ – ^85,^ ^87,^ ^88,^ ^97,^ ^98,^ ^100,^ ^103^ – ^106,^ ^110,^ ^111,^ ^113,^ ^118,^ ^120,^ ^131,^ ^135,^ ^136^ four for anxiety disorders, ^90,^ ^91,^ ^101,^ ^109^ and one for alcohol at-risk behavior. ^126^ However, possibly due to small numbers for many of them, only two studies used the information to conduct subgroup analyses. Both IMPACT ^137^ and Partners in Care ^6^ found in general no differences in outcomes between minority and nonminority populations. There was evidence of differential effects that suggest integrated care interventions may have improved quality of care for minority populations. Latinos were found to have larger use of processes of care ^137^ and lasting long-term effects of psychotherapy, ^6^ while Blacks showed greater improvements in depression scores ^137^ and similar lasting effects of psychotherapy, as compared to Whites. ^6^ While elderly people in poverty may start out with worse scores and take longer to manifest improvements in physical health benefit, they do show similar benefits from integrated care programs to people in middle- and upper-income categories. In addition, while the Asarnow et al. trial did not specifically analyze outcomes by ethnic status, the study population was predominately nonwhite, with the majority being Hispanic/Latino. ^114^ Thus, from the limited evidence, it appears that integrated care programs do not negatively impact minority and vulnerable populations, and may serve them well.

One study found in a preplanned subgroup analysis that the integrated care intervention based on a depression disease management program was effective for urban patients but not effective for rural patients with depression, even though the intervention improved guideline concordant care during the acute phase of treatment. ^138^ This differential finding from the QuEST trial is not entirely consistent with findings from other studies which included rural populations, such as Fortney et al. ^131^ The trials differed in whether or not care managers were used and length of intervention.

There is a concern that integrated care models targeted at specific mental health disorders may not be effective for patients with mental and physical comorbid conditions. One analysis of IMPACT data ^139^ showed that patients with comorbid panic disorder showed similar improvements to those without comorbidities. Patients with post-traumatic stress disorder (PTSD) showed a delayed response to intervention treatment but had caught up to other intervention patients in improvements by 12 months. Patients with reduced cognitive abilities were found to also benefit from integrated care for depression. ^140^

Integrated care models have been found to be less effective for patients with higher pain levels, ^8^ especially for patients with major depression. ^141^ However, integrated care for depression has also been shown to reduce pain associated with arthritis, with a larger effect size for higher pain levels. ^128^

Physical comorbidities do not appear to moderate effects of integrated care for depression. ^10,^ ^11^ Authors of one study inferred that an association between medical comorbidity and treatment outcomes for major depression is determined by the intensity of the depression treatment. ^11^ That is, patients with specific types of comorbidities showed greater improvement with integrated care than patients with the same comorbidities who received usual care. The Pathways trial found that diabetics with a higher number of complications derived the greatest benefit from integrated care. ^12^ Like patients in the Pathways trial, patients with diabetes in the IMPACT trial appeared to also benefit from integrated depression care. ^142^ However, for anxiety patients, higher levels of comorbidity did appear to moderate the effects of integrated care. ^9^

One of the more interesting sets of findings was on the differential impact of integration programs for patients with differing psychological makeup. Integrated care for depression appeared to be more effective than usual care for patients who score high on hopelessness ^135^ or are less likely to establish a trust relationship with providers. ^143^

There were reported gender differences in integrated care programs for depression. A qualitative study of IMPACT patients found that men and women have different views of depression. ^144^ The Partners in Care trial found women more likely to benefit from the medication arm while men were more likely to benefit from the therapy arm. ^13^

Anxiety disorder studies were, expectedly, not as developed in subgroup analysis. One study looked at medical comorbidity and found that more severely medically ill patients in the intervention group showed the most improvement over time, and were more likely to be using guideline-concordant medication for their anxiety disorder. ^9^ Similarly, Zanjani and colleagues looked at predictors of treatment initiation for at-risk alcohol behavior patients in the PRISM-E study. ^145^ They reported that patients identified by stages of change theory as pre-contemplative or actually contemplating change were more likely to initiate treatment if they were assigned to integrated care rather than enhanced referral. This may be related to what many believe is integrated care's ability to overcome stigma barriers.

### Key Question 3: What are the Identified Barriers to Successful Integration? How were Barriers Overcome? What are the Barriers to Sustainability?

There is a rich literature documenting the barriers to integrating mental health care and primary care. ^61,^ ^146^ – ^148^ As shown in Table 11, we divide these into financial and organizational barriers and note where the clinical trials reviewed explicitly address these barriers. In addition, we include supplemental material from case studies in the literature that illustrates the nature of the barriers and potential solutions. Finally, we draw on evaluations of the sustainability of the IMPACT and RESPECT-D trials that point to barriers and facilitators of success.

Table 11 Functional and quality of life outcomes

Outcome Project or Author | Measurement | Patient Category | Assessment Period | Direction of Effect | Results | Comment
DEPRESSION
Functioning/Disability
IMPACT ^2,^ ^121,^ ^130^ | SF12 overall functional impairment | | 3 months | Intervention | -0.67, 95% CI -0.9; -0.4, p<.001
IMPACT ^2,^ ^121,^ ^130^ | SF12 overall functional impairment | | 6 months | Intervention | -0.35, 95% CI -0.6; -0.5, p<.02
IMPACT ^2,^ ^121,^ ^130^ | SF12 overall functional impairment | | 12 months | Intervention | -1.03, 95% CI -1.31; -0.74, p<.0001
IMPACT ^2,^ ^121,^ ^130^ | SF12 overall functional impairment | | 18 months | Intervention | -0.47, 95% CI -0.74; -0.19, p=.0009
IMPACT ^2,^ ^121,^ ^130^ | 24 months | | NS
IMPACT ^2,^ ^121,^ ^130^ | IADLs | | 3 months | | NS
IMPACT ^2,^ ^121,^ ^130^ | IADLs | | 6 months | | NS
12 months | | -1.5, 95% CI -0.29; -0.01, p=.04
QuEST ^5,^ ^181^ | Patient work productivity (self-rated) | All patients | 2 years | Intervention | P<.05 | Estimated value of $1491 per depressed FTE
QuEST ^5,^ ^181^ | Patient work productivity (self-rated) | Consistently employed patients | 2 years | Intervention | P=.02 | Estimated value of $1982 per depressed FTE
QuEST ^5,^ ^181^ | Inconsistently employed patients | 2 years | | NS
QuEST ^5,^ ^181^ | Patient absenteeism | All patients | 2 years | | NS | Trending for intervention at P<.06. Absenteeism reduced by 10.6 days over 2 years, value of $539 per depressed FTE
QuEST ^5,^ ^181^ | Patient absenteeism | Consistently employed patients | 2 years | | NS | Trending for intervention at p<.08. Absenteeism reduced by 12.3 days over 2 years, value of $619 per depressed FTE
QuEST ^5,^ ^181^ | Inconsistently employed patients | 2 years | | NS
QuEST ^5,^ ^181^ | SF36 Emotional role functioning | | 2 years | Intervention | P=.002 | Treatment × time
SF36 Physical role functioning | | 2 years | Intervention | P=.005 | Treatment × time
Finley, 2003 ^108^ | Work and social disability scale | | 6 months | | NS
Partners in Care ^122^ | SF12 Role limitations | QI-meds | 6 months | Intervention | P<.05
Partners in Care ^122^ | SF12 Role limitations | QI-meds | 12 months | Intervention | P<.05
Partners in Care ^122^ | SF12 Role limitations | QI-meds | 18 months | | NS
Partners in Care ^122^ | SF12 Role limitations | 24 months | | NS
Partners in Care ^122^ | SF12 Role limitations | QI-therapy | 6 months | Intervention, usual care and QI-meds | P<.05
Partners in Care ^122^ | SF12 Role limitations | QI-therapy | 12 months | Intervention, usual care and QI-meds | P<.05
Partners in Care ^122^ | SF12 Role limitations | QI-therapy | 18 months | Intervention | P<.05
24 months | | NS
Hedrick, 2003 ^87^ | Sheehan disability scale | | 3 months | Intervention | -0.53, 95% CI -1.04; -0.02, p<.05
9 months | | NS
Katon, 1999 ^3,^ ^182^ | Sheehan disability scale | All patients | 1 month | | NS
Katon, 1999 ^3,^ ^182^ | Sheehan disability scale | All patients | 3 months | Intervention | P=.05
Katon, 1999 ^3,^ ^182^ | Sheehan disability scale | All patients | 6 months | | NS
Katon, 1999 ^3,^ ^182^ | Sheehan disability scale | 28 months | Intervention | P=.04 | Treatment × time
Katon, 1999 ^3,^ ^182^ | Sheehan disability scale | Moderate severity | 28 months | | NS
Katon, 1999 ^3,^ ^182^ | High severity | 28 months | | NS
Katon, 1999 ^3,^ ^182^ | SF36 social functioning | | 6 months | | NS
SF36 role functioning | | 6 months | | NS
Physical Quality of Life
Fortney, 2006 ^92^ | SF12V PCS | | 6 months | No difference | NS
12 months | No difference | NS
IMPACT ^2,^ ^130^ | SF12 general health | | 12 months | Intervention | -0.32, 95% CI -0.42; -0.22, p<.0001
IMPACT ^2,^ ^130^ | SF12 general health | | 18 months | Intervention | -0.19, 95% CI -0.42; -0.22, p=.0002
IMPACT ^2,^ ^130^ | 24 months | Intervention | -0.17, 95% CI -0.27; -0.06, p=.0015
IMPACT ^2,^ ^130^ | SF12 PCS | | 3 months | Intervention | 1.08, 95% CI 0.36; 1.80, p=.003 | Secondary analysis showed difference in functional status at 1 year accrued to those patients who showed improvement in depression symptoms.
IMPACT ^2,^ ^130^ | SF12 PCS | | 6 months | Intervention | 1.57, 95% CI 0.78; 2.34, p<.001 | Secondary analysis showed difference in functional status at 1 year accrued to those patients who showed improvement in depression symptoms.
IMPACT ^2,^ ^130^ | SF12 PCS | | 12 months | Intervention | 1.71, 95% CI 0.96; 2.47, p<.0001 | Secondary analysis showed difference in functional status at 1 year accrued to those patients who showed improvement in depression symptoms.
IMPACT ^2,^ ^130^ | SF12 PCS | | 18 months | Intervention | 1.14, 95% CI 0.34; 1.93, p=.0050 | Secondary analysis showed difference in functional status at 1 year accrued to those patients who showed improvement in depression symptoms.
24 months | Intervention | 0.83, 95% CI 0.01; 1.64, p=.0481
Clarke, 2005 ^83^ | SF12 PCS | | 12 months | | NS
Partners in Care ^122,^ ^123^ | SF12 PCS | All interventions | 6 months | | NS
Partners in Care ^122,^ ^123^ | SF12 PCS | 12 months | | NS
Partners in Care ^122,^ ^123^ | SF12 PCS | QI-meds | 6 months | | NS
Partners in Care ^122,^ ^123^ | SF12 PCS | QI-meds | 12 months | | NS
Partners in Care ^122,^ ^123^ | SF12 PCS | QI-meds | 18 months | | NS
Partners in Care ^122,^ ^123^ | SF12 PCS | 24 months | | NS
Partners in Care ^122,^ ^123^ | SF12 PCS | QI-therapy | 6 months | | NS
Partners in Care ^122,^ ^123^ | SF12 PCS | QI-therapy | 12 months | | NS
Partners in Care ^122,^ ^123^ | SF12 PCS | QI-therapy | 18 months | | NS
24 months | | NS
Hedrick, 2003 ^87^ | SF36 PCS | | 3 months | | NS
9 months | | NS
Boudreau, 2002 ^175^ | SF12 PCS | | 12 months | | NS
Mental Quality of Life
Fortney, 2006 ^92^ | SF12V MCS | | 6 months | | NS
12 months | Intervention | Effect size 0.46
PRISM-E ^118^ | SF36 MCS | Major depression | 3 month
PRISM-E ^118^ | SF36 MCS | 6 month | | NS
PRISM-E ^118^ | SF36 MCS | Other depression | 3 month
PRISM-E ^118^ | SF36 MCS | 6 month | | NS
PRISM-E ^118^ | SF36 MCS | All depression | 3 month
6 month | | NS
Clarke, 2005 ^83^ | SF12 MCS | | 12 months | | Effect size 0.203
Partners in Care ^122,^ ^123^ | SF12 MCS | All interventions | 6 months | All interventions | P=.009
Partners in Care ^122,^ ^123^ | SF12 MCS | 12 months | All interventions | P=.04
Partners in Care ^122,^ ^123^ | SF12 MCS | QI-meds | 6 months | | NS
Partners in Care ^122,^ ^123^ | SF12 MCS | QI-meds | 12 months | | NS
Partners in Care ^122,^ ^123^ | SF12 MCS | QI-meds | 18 months | | NS
Partners in Care ^122,^ ^123^ | SF12 MCS | QI-meds | 24 months | | NS
Partners in Care ^122,^ ^123^ | SF12 MCS | 5 years | | NS
Partners in Care ^122,^ ^123^ | SF12 MCS | QI-therapy | 6 months | Intervention | P<.05
Partners in Care ^122,^ ^123^ | SF12 MCS | QI-therapy | 12 months | Intervention | P<.05
Partners in Care ^122,^ ^123^ | SF12 MCS | QI-therapy | 18 months | Intervention | P<.05
Partners in Care ^122,^ ^123^ | SF12 MCS | QI-therapy | 24 months | Intervention | P<.05
5 years | | NS
Hedrick, 2003 ^87^ | SF36 MCS | | 3 months | | NS
9 months | | NS
Boudreau, 2002 ^175^ | SF12 MCS | | 12 months | | NS
Hunkeler, 2000 ^110^ (reporting telehealth nurse only, not peer support) | SF12 MCS | | 6 weeks | Intervention | P=.004
6 months | | NS
Asarnow, 2005 ^114^ | SF12 MCS | | 6 months | Intervention | 2.6, 95% CI 0.3, 4.8, p=.03
Wellbeing
Fortney, 2006 ^92^ | Change in Quality of Well Being score | | 6 months | Intervention | Effect size 1.43
12 months | | NS
IMPACT ^121^ | SF12 overall quality of life in past month | | 3 months | Intervention | 0.49, 95% CI 0.27; 0.69, p<.001
IMPACT ^121^ | SF12 overall quality of life in past month | | 6 months | Intervention | 0.41, 95% CI 0.17; 0.63, p<.001
12 months | Intervention | 0.56, 95% CI 0.32; 0.79, p<.001
Patient Self-efficacy
IMPACT ^2^ | Confidence managing depression | | 12 months | Intervention | 0.77, 95% CI 0.55; 0.99, p<.0001
24 months | Intervention | 0.39, 95% CI 0.16; 0.62, p=.001
ANXIETY DISORDERS
Functioning/Disability
Roy-Byrne, 2001 ^109^ | SF36 Role functioning | | 12 months | Intervention | P=.03
SF36 Social functioning | 12 months | | NS
CCAP ^9^ | WHO disability scale | | 3 months | Intervention | Effect size 0.29
CCAP ^9^ | WHO disability scale | | 6 months | Intervention | Effect size 0.31
CCAP ^9^ | WHO disability scale | | 9 months | Intervention | Effect size 0.33
12 months | Intervention | Effect size 0.34
EMPLOYMENT STATUS
Physical Quality of Life
CCAP ^9^ | SF12 PCS | | 3 months | | NS
CCAP ^9^ | SF12 PCS | | 6 months | | NS
CCAP ^9^ | SF12 PCS | | 9 months | | NS
12 months | | NS
Rollman, 2005 ^101^ | SF12 PCS | All patients | 12 months | | NS
Mental Quality of Life
CCAP ^9^ | SF12 MCS | | 3 months | Intervention | Effect size 0.33
CCAP ^9^ | SF12 MCS | | 6 months | Intervention | Effect size 0.27
CCAP ^9^ | SF12 MCS | | 9 months | | NS
12 months | | NS
Rollman, 2005 ^101^ | SF12 MCS | All patients | 12 months | Intervention | 0.39, 95% CI 0.10; 0.68, p=.03 | Intervention × time
Rollman, 2005 ^101^ | SF12 MCS | Panic disorder | 12 months | Intervention | 0.50, 95% CI 0.11; 0.89, p=.004 | Intervention × time
General anxiety disorder | 12 months | | NS
OTHER DISORDERS
Mental Quality of Life
PRISM-E ^126^ | SF-12 MCS | | 6 months | | NS

Financial barriers. The financial barriers to integrating mental health care into primary care have been well-documented and many have concluded that such barriers are major impediments to achieving clinical integration outside of the clinical trial environment. ^149^ – ^152^ Table 11 summarizes these barriers and gives examples of strategies that have been used to overcome them. For many persons, behavioral health services are carved out from the general medical care benefits and managed by a separate managed behavioral health organization (MBHO). Thus, benefit designs often prohibit reimbursement for mental health services by primary care physicians (except usually the initial visit), and there is no financial mechanism for coordination across physicians who are contracted on separate panels. If providers are practicing under capitation, there is a further incentive to refer patients to mental health specialty care and to not treat within primary care.

Health plans typically do not reimburse for consultation between providers, team meetings, or telephone calls. Similarly, health plans differ widely in how likely they are to reimburse for case management services. ^149^ Moreover, while there are Current Procedural Terminology (CPT) codes for care management services, the amount of reimbursement for the coded service is insufficient to meet salary and benefit needs of professionals. Further, for most services face-to-face clinical assessment/intervention is required for billing, yet much of care management is done telephonically.

Most of the clinical trials reviewed did not confront these financial barriers because they were at least partially funded with research funding. While some organizations involved in these trials (i.e., Project IMPACT), included sites that managed mental health care under carve-outs, the financing of the program did not reflect these arrangements; encounters with the care manager and psychiatrist were provided free to patients in IMPACT. ^121^ RESPECT-D, in contrast, was designed to demonstrate the feasibility of implementing collaborative care in ‘real world’ settings, and included financing through the participating organizations' quality improvement budgets. However, even RESPECT-D faced financial difficulties sustaining care manager functions under this model. ^153^

The best evidence of strategies to overcome these barriers in real world settings comes from projects funded through the Robert Wood Johnson Foundation's Depression in Primary Care: Linking Clinical and System Strategies program. ^62,^ ^154^ The program funded a number of initiatives (under the Incentive Demonstration Projects) focused on addressing the financial integration of mental health and primary care services. While these have not been fully evaluated, they do offer some strategies for overcoming some of the common barriers to financial integration. The experiences of Colorado Access (a Medicaid health plan that provided carved out behavioral health services) and the University of California San Francisco (UCSF) (a partnership between their network of primary care practices, a general medical plan and carved out behavioral health services) demonstrate how integration efforts can be funded even in carved-out environments. Both sites changed reimbursement rules so that primary care physicians could bill for mental health care. Colorado Access, however, had physicians bill the general medical plan for mental health visits, while the initiative at UCSF involved negotiations with the carve-out so that credentialed primary care physicians could bill the MBHO for services.

The University of Michigan demonstration project ^155^ offers yet another model of financial integration. The University of Michigan Health System (UMHS) partnered with Ford Motor Company to provide depression care in primary care practices for members enrolled in two regional health plans. The project went to substantial efforts to first price the care management services introduced into primary care and used a combination of existing CPT codes and the new codes to bill based on resource units. Thus, unlike Colorado Access or the UCSF initiative, the UMHS integration effort involved billing for ‘new’ services. ^154^

One of the central difficulties to achieving financial integration is that any given practice is likely to treat patients from multiple insurance plans. Barry and Frank ^154^ estimate a typical medical group is covered by 10 to 15 health plans. Thus, full integration is possible only if each plan is willing to participate, a formidable challenge. Barry and Frank ^154^ report, for example, that although the UCSF initiative achieved remarkable partnerships between their primary care clinics, the MBHO and the general medical care plan, this covered only a minority of patients for most physicians.

#### Organizational barriers

Change. The efforts to achieve integration are substantial, and providers may be reluctant to invest in such efforts. Primary care providers have been trained to provide general medical services and often consider mental health services outside of their responsibility, although views of responsibility varies by specialty. ^156^ A key determinant of successful organizational integration programs is having a key leader (or leaders) who are willing to promote, support, and advocate for the program. While much has been written about the importance of leadership, ^146,^ ^157,^ ^158^ most of the clinical trials reviewed do not directly address this aspect of program implementation. Project IMPACT, RESPECT-D, and PROSPECT, did identify key leaders as part of the implementation of the interventions ^146^ but do not describe how these leaders were identified or how commitment of leaders was sustained.

Time. Asking primary care physicians to take additional responsibility for their patients' mental health problem must be balanced against the myriad of other patient needs. None of the studies directly access the impact of integrating care on physicians' workloads. However, Thomas and colleagues ^159^ report that many of the physicians who participated in the RESPECT-D trial from the Colorado Access initiative felt that the time it took to screen patients was a barrier to sustainability. Similarly, Rost and colleagues report substantial problems implementing an integrated model that included first stage screening to identify patients at risk for depression, followed by a second stage screener to confirm eligibility. ^111^ Approximately one in five patients screened positive at the first stage, more than the staff were able to initially process through the second screener. To adjust, staff relaxed criteria that every patient be screened and subsequently the research team hired further screeners to help with the workload. One possible strategy is to centralize screening (for example, have the health plan conduct the screening). ^159^

The use of physician extenders (or care managers) to provide care management functions should mitigate some time pressures on primary care physicians. In most of the trials, these professionals were responsible for monitoring patients, providing feedback to clinicians, and often acting as a liaison between primary and specialty care. This should, in theory, reduce the time that primary care physicians need to devote to caring for patients with mental health problems such as depression. None of the research reports the effects of such efforts on physician workloads. Moreover, as mentioned previously, there remain substantial financial barriers to adding such roles in practices.

The collaborative care models that rely on care managers are premised on having a sufficient caseload to finance such a position. Project PROSPECT estimated that a feasible caseload for their health specialist (who took on role as liaison with physicians, and provided some psychotherapy services) is approximately 30 patients. ^160^ Other research, however, has found estimates in the 100–150 range, depending on care management role responsibilities and work flow requirements. ^73,^ ^161^ For many practices that are small or that are located in rural areas where access to psychiatry is problematic, training such care managers to practice onsite is not feasible. As Barry and Frank ^154^ point out, most physicians work in relatively small practices (nine or fewer physicians) and thus the cost of supporting a care manager may be prohibitive. One possible solution is to rely more heavily on telemedicine. Fortney and colleagues, for example, tested an integrated model that used off-site professionals (including case managers, psychiatrists, and pharmacists) who worked with the on-site primary care physicians in a rural site. ^131^

The introduction of new roles to support primary care physicians does not guarantee that the roles will function as designed. In the clinical trial reported by Swindle and colleagues, clinical nurse specialists (CNSs) were trained to provide care management functions and liaison with primary care physicians. ^85^ However, many of the CNSs did not agree with the screening method to identify cases with depression, and many failed to develop a treatment plan for patients. The authors speculate that because the CNSs were accountable to the mental health service, not the primary care service, they may been less committed to mental health treatment within the PCP sector and more willing to utilize ‘watchful waiting’ rather than evidence based guidelines for care.

Finally, there are issues around privacy that may be a barrier to organizational integration. The regulations under the Health Insurance Portability and Accountability Act (HIPAA) are sometimes misinterpreted as intended to prohibit the sharing of medical information between providers without the patients' consent. However, HIPAA does not prohibit these practices, although some state and federal laws or practices have privacy laws that are more restrictive and may prevent effective communication. ^62^ None of the trials reviewed reported on how they addressed privacy concerns.

Sustainability. The barriers to integrated care have often made it difficult to sustain the models developed in clinical trials in real world settings. There have been followups of both RESPECT-D and IMPACT that point to some of the important barriers to sustainability.

RESPECT-D investigators conducted a 1 year and 3 year followup of the five health care organizations (two health plans and three medical groups) originally involved in the trials. ^153^ At 1 year, they assessed referrals to care management for each organization. They found that three of the organization (all the medical groups) continued to utilize care management, but that the number of referrals from physicians was substantially lower in the 1-year period after the intervention compared to the prior year when the clinical trial was operating. Moreover, clinicians seemed to be unaware of the available services. Less than half the clinicians reported that their organization made a psychiatrist available for consultation (although four out of five of the organizations did have this service available). Similarly, although all sites had care management available, at 3 years 40 percent of clinicians said that such services were not available.

The method of referral to care management was substantially modified at one of the health plans, with referral to care management primarily done by the plan after identifying patients through administrative data. At the other health plan, care management was transferred to an external disease management company. The authors conclude that although the key components of RESPECT-D were maintained in three sites, the health plans were less successful in maintaining the core elements. The authors speculate that this may have been because the plans are less connected to the clinical care of patients than are medical groups and thus may have been less committed. The authors also report that financial barriers continued to be a problem. The project was designed to be supported by the organization's quality improvement funds. However, at followup, funds were made available to the plans that participated in the study to help with the transition to post-study activity, and that further modifications to the model may have been made had the funds not been available.

Project IMPACT investigators conducted a similar evaluation, including accessing how the intervention was implemented at each of the seven sites and whether the intervention was sustained 1 year following the end of the trial. ^162^ While they found that the major components of IMPACT remained at five of the seven sites, they were substantially adapted. The staffing of the care manager role was substantially changed in four of the five sites that sustained the intervention, typically with other professionals than clinical nurse specialists fulfilling the role. In two of the sites, the care manager role was expanded to address more than depression care (i.e., diabetes). The use of psychiatrists as supports was also substantially changed, and came to more closely resemble ‘usual care’ at some sites. Instead of being available to see patients in the primary care setting, psychiatrists were available for consult or referral. There were also modifications in the use of the PHQ-9 to track clinical status, patient educational tools, and use of psychotherapy. The authors also assessed barriers to sustainability through interviews with key informants at each site. Some of the health care organizations resisted change, either because they felt they had sufficient programs in place (one site) or their practices were geographically dispersed so the position of a care manager at each site was not feasible.

At all of the sites, financial barriers were substantial, particularly those involving funding of the care manager role. The five sites that continued IMPACT varied widely in funding models. Only one site was able to directly bill insurance plans for care management services. The other sites maintained the model by having the organization directly support the position, connecting it to other programs (i.e., an existing disease management program or an existing geriatric research project). The authors argue that demonstrating clinical effectiveness helped secure funding in one site, and may be critical to sustainability.

Of all the models of integration that have been tested, Project IMPACT has gone the farthest in trying to facilitate the implementation of collaborative care in real world settings. The investigators are currently working toward establishing IMPACT in a diverse array of settings, and provide support to sites implementing the intervention. ^163^ However, currently projects implemented under the IMPACT model are not being evaluated for fidelity to the core elements of the models, so it may be difficult to isolate specific features of the models likely to reduce barriers.

The VA is also committed to investigating and implementing integrated care processes across VA settings. More will be provided on the VA's efforts in a later case study in Chapter 4 of the report.

### Key Question 4: To What Extent did Successful Integration Programs Make Use of Health IT?

Health IT is one of the core elements of the Wagner CCM, because it holds great promise for improving integration between primary care and specialty mental health providers. Types of health IT, to name a few, include the electronic health record (EHR), health information exchange, electronic prescribing of medications, internet or web-based provider and patient education, and telemedicine technologies. Overall, we found that reporting in the literature on the uses of health IT by successful integration programs is scant. We describe in this section several uses of health IT to improve integration processes of care, as illustrated in Figure 1 in Chapter 1 and Table 12, (1) systematic screening and case identification, (2) communication between primary care and specialty mental health providers, (3) decision support, (4) monitoring of clinical status and medication adherence, and (5) treatment delivery (e.g., telemedicine). This section is primarily descriptive in nature and, given the scant literature on this topic, we are limited in our ability to comment on the effectiveness or impact of specific types of health IT for improving integration processes of care.

Table 12 Process or program outcomes and utilization

Outcome Project or Author | Measurement | Patient Category | Assessment Period | Direction of Effect | Results | Comment
DEPRESSION
Adherence/Adequate Dosage
Fortney, 2006 ^92^ | Full dosage ≥80% of days | | 6 months | Intervention | NNT=8
12 months | Intervention | NNT=6
Fortney, 2006 ^131^ | Proportion of patients with active prescription, EMR source | | 6 months | | NS
12 months | | NS
Pathways ^113^ | Any antidepressant refills | | 3 months | Intervention | OR 3.20, 95% CI 1.84; 5.58
Pathways ^113^ | Any antidepressant refills | | 6 months | Intervention | OR 2.29, 95% CI 1.38; 3.82
Pathways ^113^ | Any antidepressant refills | | 9 months | Intervention | OR 2.78, 95% CI 1.62; 4.76
Pathways ^113^ | 12 months | Intervention | OR 2.18, 95% CI 1.32; 3.62
Pathways ^113^
Pharmacy records, based on guidelines | | 1–6 months | Intervention | OR 4.15, 95% CI 2.28; 7.55
7–12 months | Intervention | OR 2.9, 95% CI 1.69; 4.98
Adler, 2004 ^106^ | Rate of antidepressant use, self-report | | 3 months | Intervention | P=.024 | High of 60.6% of patients using antidepressants at 3 months. Impact greatest for those not on antidepressants at baseline
6 months | Intervention | P=.025
Finley, 2003 ^108^ | HEDIS antidepressant adherence rate | | 3 months | | NS
6 months | Intervention | P=.038 | 67% of patients using antidepressants in continuation phase.
Partners in Care ^183^ | Any antidepressant use in past 6 months | | 6 months | PIC-Meds | P=.001 | Compared to usual care. Also significantly greater than PIC-Therapy at 6, 12, and 24 months.
Partners in Care ^183^ | Any antidepressant use in past 6 months | | 12 months | PIC-Meds | P=.003 | Compared to usual care. Also significantly greater than PIC-Therapy at 6, 12, and 24 months.
Partners in Care ^183^ | Any antidepressant use in past 6 months | | 18 months | | NS | Compared to usual care. Also significantly greater than PIC-Therapy at 6, 12, and 24 months.
24 months | | NS
Datto, 2003 ^97^ | Treatment adherence, medication and psychotherapy if receiving care at baseline | | 16 weeks | | NS | Adherence was not predicted by age, gender, baseline physical and mental health status, or depression severity
Katon, 1999 ^3,^ ^103^ | Adhere ≥90 days of adequate dosage | All patients | 1–6 months | Intervention | P<.001 | 73% of intervention
Katon, 1999 ^3,^ ^103^ | Adhere ≥90 days of adequate dosage | All patients | 7–12 months | | NS
Katon, 1999 ^3,^ ^103^ | Adhere ≥90 days of adequate dosage | 11–28 months | | NS
Katon, 1999 ^3,^ ^103^ | Adhere ≥90 days of adequate dosage | Moderate severity | 1–6 months | Intervention | P<.05 | 76% of intervention
Katon, 1999 ^3,^ ^103^ | Adhere ≥90 days of adequate dosage | Moderate severity | 7–12 months | | NS
Katon, 1999 ^3,^ ^103^ | Adhere ≥90 days of adequate dosage | 11–28 months | | NS
Katon, 1999 ^3,^ ^103^ | Adhere ≥90 days of adequate dosage | High severity | 1–6 months | Intervention | P<.01 | 72% of intervention
Katon, 1999 ^3,^ ^103^ | Adhere ≥90 days of adequate dosage | High severity | 7–12 months | Intervention | P<.05 | 70% of intervention
Katon, 1999 ^3,^ ^103^ | 11–28 months | | NS
Katon, 1999 ^3,^ ^103^ | Adequate low-dose for 90 days, AHRQ guideline | | 6 months | Intervention | P<.0001
Adequate moderate-dose for 90 days, psychiatrist practice | | 6 months | Intervention | P=.002
Katon, 1995 ^102^ | Adhere ≥30 days of adequate dosage | Minor depression | 1–7 months | Intervention | P<.001
Katon, 1995 ^102^ | Major depression | 1–7 months | Intervention | P<.001
Katon, 1995 ^102^ | Adhere ≥90 days of adequate dosage | Minor depression | 1–7 months | Intervention | P<.001
Major depression | 1–7 months | Intervention | P<.01
Katon, 1996 ^88^ | Adhere ≥30 of adequate dosage | Major depression | 7 months | | NS | Pharmacy records
Adhere ≥30 of adequate dosage | Minor depression | 7 months | Intervention | P<.002
Katon, 2001 ^98^ | Any antidepressant refill | | 12 months | Intervention | 0.90, 95% CI 1.37; 2.65, p<.001
Adequate dosage | | 12 months | Intervention | OR 2.08, 95% CI 1.41; 3.06
Boudreau, 2002 ^175^ | Use of antidepressants for at least 25 of past 30 days | | 12 months | | NS
Simon, 2004 ^84^ | Adequate pharmacotherapy for 90 days | Telephone psychotherapy plus care management | 6 months | | NS
Telephone care management | 6 months | Intervention | P=.01 | 54% received adequate dosage
Tutty, 2000 ^89^ | Adequate low-dose for 90 days, AHRQ guideline | | 3 months | | NS
Tutty, 2000 ^89^ | 6 months | | NS
Tutty, 2000 ^89^ | Adequate moderate-dose for 90 days, psychiatrist practice | | 3 months | | NS
6 months | | NS
Lin, 1999, followup of Katon, 1995 and 1996 ^4^ | Adequate pharmacotherapy | | 19 months | | NS
Simon, 2000 ^99^ | Adequate low-dose for 90 days, AHRQ guideline | Care management arm | 6 months | | NS
Adequate moderate-dose for 90 days, psychiatrist practice | Care management arm | 6 months | Intervention | OR 1.99, 95% CI 1.23; 3.22
Process of Care/Program Use
Grypma, 2006 ^93^ | Care manager contacts | | Unclear | Post-study | 19.8 to 13.6 contacts, p<.001 | Post-study group used less care manager services than IMPACT RCT.
Grypma, 2006 ^93^ | Use of any PST-PC | | Unclear | | NS | Post-study group used less care manager services than IMPACT RCT.
Use of antidepressant | | Unclear | | NS
IMPACT ^2,^ ^121^ | Percent self-reported use of antidepressant | | 3 months | Intervention | OR 2.02, 95% CI 1.66; 2.44, p<.001 | 12 months showed highest percent using antidepressants in intervention (73%)
IMPACT ^2,^ ^121^ | Percent self-reported use of antidepressant | | 6 months | Intervention | OR 2.02, 95% CI 1.66; 2.47, p<.001 | 12 months showed highest percent using antidepressants in intervention (73%)
IMPACT ^2,^ ^121^ | Percent self-reported use of antidepressant | | 12 months | Intervention | 18.46, 95% CI 13.53; 23.40), p<.0001 | 12 months showed highest percent using antidepressants in intervention (73%)
IMPACT ^2,^ ^121^ | Percent self-reported use of antidepressant | | 18 months | Intervention | 14.74 95% CI 9.58; 19.89, p<.0001 | 12 months showed highest percent using antidepressants in intervention (73%)
IMPACT ^2,^ ^121^ | 24 months | Intervention | 13.91, 95% CI 8.69; 19.14, p<.0001
IMPACT ^2,^ ^121^ | Percent self-reported use of any specialty mental health visits or psychotherapy | | 3 months | Intervention | OR 3.77, 95% CI 3.02; -4.70, p<.001 | 12 months showed highest percent using mental health in intervention (43%)
IMPACT ^2,^ ^121^ | Percent self-reported use of any specialty mental health visits or psychotherapy | | 6 months | Intervention | OR 4.47 95% CI 3.47; 5.77. p<.001 | 12 months showed highest percent using mental health in intervention (43%)
IMPACT ^2,^ ^121^ | Percent self-reported use of any specialty mental health visits or psychotherapy | | 12 months | Intervention | 28.18, 95% CI 23.79; 32.57), p<.0001 | 12 months showed highest percent using mental health in intervention (43%)
IMPACT ^2,^ ^121^ | Percent self-reported use of any specialty mental health visits or psychotherapy | | 18 months | | NS | 12 months showed highest percent using mental health in intervention (43%)
IMPACT ^2,^ ^121^ | 24 months | | NS
IMPACT ^2,^ ^121^ | Percent self-reported use of any depression treatment | | 3 months | Intervention | OR 3.33, 95% CI 2.68; 4.13, p<.001 | 12 months showed highest percent using any treatment in intervention (82%)
IMPACT ^2,^ ^121^ | Percent self-reported use of any depression treatment | | 6 months | Intervention | OR 2.93, 95% CI 2.34; 3.67, p<.001 | 12 months showed highest percent using any treatment in intervention (82%)
IMPACT ^2,^ ^121^ | Percent self-reported use of any depression treatment | | 12 months | Intervention | 25.69, 95% CI 21.03; 30.35, p<.0001 | 12 months showed highest percent using any treatment in intervention (82%)
IMPACT ^2,^ ^121^ | Percent self-reported use of any depression treatment | | 18 months | Intervention | 15.19, 95% CI 10.07; 20.31, p<.0001 | 12 months showed highest percent using any treatment in intervention (82%)
24 months | Intervention | 13.78, 95% CI 8.55; 19.00, p<.0001
Pathways ^113^ | 4 or more specialty mental health visits | | 12 months | Intervention | 29.31, 95% CI 14.65; 58.66 | 67.7% of intervention patients reported 4 or more visits
PROSPECT ^125^ | Medication and psychotherapy | | 4 months | | NS
PROSPECT ^125^ | Medication and psychotherapy | | 8 months | | NS
PROSPECT ^125^ | 12 months | Increased for control | OR 0.25, 95% CI 0.07; 0.96, p<.001
PROSPECT ^125^ | Medication only | | 4 months | Increased for intervention | OR 4.91, 95% CI 2.13; 11.33, p<.001
PROSPECT ^125^ | Medication only | | 8 months | Increased for intervention | OR 4.20, 95% CI 1.77; 9.96, p<.001
PROSPECT ^125^ | 12 months | Increased for intervention | OR 7.21, 95% CI 2.86; 18.18, p<.001
PROSPECT ^125^ | Psychotherapy only | | 4 months | Increased for intervention | OR 43.93, 95% CI 11.59; 166.42, p<.001
PROSPECT ^125^ | Psychotherapy only | | 8 months | Increased for intervention | OR 163.48, 95% CI 21.90; 1220.57, p<.001
PROSPECT ^125^ | 12 months | Increased for intervention | OR 41.15, 95% CI 6.22; 272.39, p<.001
PROSPECT ^125^ | No treatment | | 4 months | Increased for control | OR 0.003, 95% CI 0; 0.02, p<.001
PROSPECT ^125^ | No treatment | | 8 months | Increased for control | OR 0.004, 95% CI 0; 0.02, p<.001
12 months | Increased for control | OR 0.02, 95% CI 0; 0.07, p<.001
RESPECT-D ^120^ | Percent taking antidepressants | | 3 months | | NS
RESPECT-D ^120^ | 6 months | | NS
RESPECT-D ^120^ | Percent received counseling in past 3 months | | 3 months | | NS
6 months | | NS
Simon, 2004 ^84^ | Primary care visits for mental health diagnosis | Telephone psychotherapy plus care management | 6 months | Increased for intervention | P=.01
Simon, 2004 ^84^ | Telephone care management | 6 months | Increased for intervention | P=.01
Simon, 2004 ^84^ | Primary care visits for other than mental health | Telephone psychotherapy plus care management | 6 months | Decreased for intervention | P=.02
Simon, 2004 ^84^ | Telephone care management | 6 months | | NS
Simon, 2004 ^84^ | Mental health specialty visits for medication management | Telephone psychotherapy plus care management | 6 months | | NS
Simon, 2004 ^84^ | Telephone care management | 6 months | | NS
Simon, 2004 ^84^ | Mental health specialty visits for psychotherapy | Telephone psychotherapy plus care management | 6 months | Decrease for intervention | P=.02
Simon, 2004 ^84^ | Telephone care management | 6 months | | NS
Simon, 2004 ^84^ | Total primary care and mental health visits | Telephone psychotherapy plus care management | 6 months | | NS
Simon, 2004 ^84^ | Telephone care management | 6 months | | NS
Simon, 2004 ^84^ | ≥4 psychotherapy sessions | Telephone psychotherapy plus care management | 6 months | Increase for intervention | P<.001
Telephone care management | 6 months | Increase for intervention | P=.01
Partners in Care ^123,^ ^136^ | Percent with overall appropriate care | All interventions | 6 months | Intervention | P<.001
Partners in Care ^123,^ ^136^ | Percent with overall appropriate care | QI-meds | 6 months | Intervention | P<.001
Partners in Care ^123,^ ^136^ | Percent with overall appropriate care | QI-therapy | 6 months | Intervention | P=.002
Partners in Care ^123,^ ^136^ | Percent with overall appropriate care | All interventions | 12 months | Intervention | P=.006
Partners in Care ^123,^ ^136^ | Percent with overall appropriate care | QI-meds | 12 months | Intervention | P<.001 | QI meds also higher than QI therapy, P=.02
Partners in Care ^123,^ ^136^ | QI-therapy | 12 months | | NS
Partners in Care ^123,^ ^136^ | Percent with appropriate antidepressant medication | All interventions | 6 months | Intervention | P=.001
Partners in Care ^123,^ ^136^ | Percent with appropriate antidepressant medication | QI-meds | 6 months | Intervention | P=.001
Partners in Care ^123,^ ^136^ | Percent with appropriate antidepressant medication | QI-therapy | 6 months | | NS
Partners in Care ^123,^ ^136^ | Percent with appropriate antidepressant medication | All interventions, if appropriate at baseline | 6 months | | NS
Partners in Care ^123,^ ^136^ | Percent with appropriate antidepressant medication | All interventions, if not appropriate at baseline | 6 months | Intervention | P<.001
Partners in Care ^123,^ ^136^ | Percent with appropriate antidepressant medication | All interventions | 12 months | Intervention | P=.01
Partners in Care ^123,^ ^136^ | Percent with appropriate antidepressant medication | QI-meds | 12 months | Intervention | P<.001
Partners in Care ^123,^ ^136^ | Percent with appropriate antidepressant medication | QI-therapy | 12 months | | NR
Partners in Care ^123,^ ^136^ | Percent with appropriate antidepressant medication | All interventions, if appropriate at baseline | 12 months | Intervention | P=.006
Partners in Care ^123,^ ^136^ | All interventions, if not appropriate at baseline | 12 months | | NS
Partners in Care ^123,^ ^136^ | Percent with any specialty counseling | All interventions | 6 months | Intervention | P<.001
Partners in Care ^123,^ ^136^ | Percent with any specialty counseling | QI-meds | 6 months | Intervention | P=.003
Partners in Care ^123,^ ^136^ | Percent with any specialty counseling | QI-therapy | 6 months | Intervention | P<.001
Partners in Care ^123,^ ^136^ | Percent with any specialty counseling | All interventions, if counseled prior to baseline | 6 months | | NS
Partners in Care ^123,^ ^136^ | Percent with any specialty counseling | All interventions in not counseled prior to baseline | 6 months | Intervention | P<.001
Partners in Care ^123,^ ^136^ | Percent with any specialty counseling | All interventions | 12 months | Intervention | P=.03
Partners in Care ^123,^ ^136^ | Percent with any specialty counseling | QI-meds | 12 months | Intervention | P=.003
Partners in Care ^123,^ ^136^ | Percent with any specialty counseling | QI-therapy | 12 months | | NR
Partners in Care ^123,^ ^136^ | Percent with any specialty counseling | All interventions, if counseled prior to baseline | 12 months | | NS
Partners in Care ^123,^ ^136^ | All interventions in not counseled prior to baseline | 12 months | Intervention | P=.05
Measures of use of psychotherapy | QI-med, QI-therapy, usual care | 2 years | | | QI-therapy showed significantly higher use of high and low doses of psychotherapy, CBT-type therapy, number of session. Major depression was driver of different use patterns.
| Measures of use of medication | QI-med, QI-therapy, usual care | 2 years | | | QI-med had significantly higher rates of antidepressant use and reduction in long-term minor tranquilizer use compared to QI-therapy or usual care.
Hedrick, 2003 ^87^ | Percent receiving antidepressants | | 9 months | Intervention | P<.0001 | 80% intervention patients received antidepressants
Katon, 1999 ^103^ | Mean PCP visits | | 12 weeks | | NS
Katon, 1999 ^103^ | 6 months | | NS
Katon, 1999 ^103^ | Percent with at least one non-study mental health visit | | 12 weeks | | NS
Katon, 1999 ^103^ | 6 months | | NS
Katon, 1999 ^103^ | Mean non-study mental health visits | | 12 weeks | | NS
6 months | | NS
QuEST ^5^ | Use of antidepressants | | 24 months | Intervention | P<.0001 | Intervention group used 6.5 months vs. 3.4 months for control group
QuEST ^5^ | Use of mental health counseling | | 6 months | Intervention | P<.0001
QuEST ^5^ | Use of mental health counseling | | 12 months | | P=.01
QuEST ^5^ | Use of mental health counseling | | 18 months | | NS
24 months | | NS
Asarnow, 2005 ^114^ | Any specialty mental health care | | 6 months | Intervention | OR 2.8, 95% 1.6, 4.9, p<.001
Asarnow, 2005 ^114^ | Any psychotherapy or counseling | | 6 months | Intervention | OR 2.2, 95% 1.3, 3.9, p=.007
Asarnow, 2005 ^114^ | Number of counseling visits | | 6 months | Intervention | OR 2.4, 94% CI 1.4, 4.1, p=.003
Asarnow, 2005 ^114^ | Any medication | | 6 months | | NS
Any mental health treatment by primary care clinical | | 6 months | | NS
Satisfaction with Treatment
Fortney, 2006 ^131^ | Total behavioral health satisfaction, Experience of Care and Health Outcomes Survey | | 6 months | Intervention | NNT=8
12 months | Intervention | NNT=9
PRISM-E ^184^ | Client satisfaction questionnaire | | 12 months | Integrated care | Mean score 3.4 vs. 3.2, p<.001 | Driven by referral care indicating lower level of “services received met your needs.” Those with lower SES and higher perceived stigma were less likely to be satisfied.
IMPACT ^2,^ ^121^ | Satisfaction with depression care | | 3 months | Intervention | OR 3.26, 95% CI 2.52; 4.22, p<.001
IMPACT ^2,^ ^121^ | Satisfaction with depression care | | 12 months | Intervention | 27.95, 95% CI 22.45; 33.45, p<.0001
IMPACT ^2,^ ^121^ | Satisfaction with depression care | | 18 months | Intervention | 14.11, 95% CI 7.91; 20.30, p<.0001
24 months | Intervention | 12.96, 95% CI 6.48; 19.44, p=.0001
Clarke, 2005 ^83^ | Satisfaction with care | | 12 months | | NS
Pathways ^113^ | Satisfaction with treatment | | 6 months | Intervention | OR 2.01, 95% CI 0.57; 1.40
12 months | Intervention | OR 2.88, 95% CI 1.67; 4.97
RESPECT-D ^120^ | Rating of care as good to excellent | | 3 months | Intervention | P=.008
6 months | Intervention | P=.0003
Simon, 2004 ^84^ | “Very satisfied” with treatment | Telephone psychotherapy plus care management | 6 months | Intervention | P<.001
Telephone care management | 6 months | Intervention | P=.001
Finley, 2003 ^108^ | Overall satisfaction with treatment | | 6 months | Intervention | P=.023 | Significant for 7 of 11 satisfaction items
Swindle, 2003 ^85^ | Overall satisfaction | | 3 months | | NS
12 months | | NS
Katon, 1999 ^103^ | Satisfaction with treatment | | 3 months | Intervention | P<.00001
Katon, 1995 ^102^ | Satisfaction with treatment | Minor depression | 4 months | | NS
Katon, 1995 ^102^ | Major depression | 4 months | Intervention | P<.03
Katon, 1995 ^102^ | Satisfaction with medication | Minor depression | 4 months | Intervention | P<.02
Major depression | 4 months | Intervention | P<.01
Katon, 1996 ^88^ | Satisfaction with treatment | Major depression | 4 months | Intervention | P<.009
Minor depression | 4 months | Intervention | P=.003
Hedrick, 2003 ^87^ | Overall satisfaction with treatment | | 9 months | | NS
Boudreau, 2002 ^175^ | Satisfaction with depression care | | 12 months | | NS
Hunkeler, 2000 ^110^ (reporting telehealth nurse only, not peer support) | Satisfaction with treatment | | 6 weeks | Intervention | P=.004
6 months | Intervention | P=.001
Asarnow, 2005 ^114^ | Satisfaction with mental health care | | 6 months | Intervention | 0.3, 95% CI 0.1, 0.5, p=.004
Guideline concordance
Datto, 2003 ^97^ | Clinician adherence with guidelines | All patients | 12 weeks | | NS
Patients who required treatment adjustment | 12 weeks | | OR 7.03, 95% CI 1.03; 48.01, p=.05
ANXIETY DISORDERS
Adherence/Adequate Dosage
Roy-Byrne, 2001 ^109^ | Adherent more than 25 days | | 3 months | Intervention | P<.05
Roy-Byrne, 2001 ^109^ | Adherent more than 25 days | | 6 months | Intervention | P<.05
Roy-Byrne, 2001 ^109^ | Adherent more than 25 days | | 9 months | | NS
12 months | | NS
Roy-Byrne, 2001 ^109^ | % received appropriate type of medication | | 3 months | Intervention | P<.05
Roy-Byrne, 2001 ^109^ | % received appropriate type of medication | | 6 months | | NS
Roy-Byrne, 2001 ^109^ | % received appropriate type of medication | | 9 months | | NS
Roy-Byrne, 2001 ^109^ | 12 months | | NS
Roy-Byrne, 2001 ^109^ | % received adequate dosage and duration | | 3 months | Intervention | P<.05
Roy-Byrne, 2001 ^109^ | % received adequate dosage and duration | | 6 months | Intervention | P<.05
Roy-Byrne, 2001 ^109^ | % received adequate dosage and duration | | 9 months | | NS
12 months | | NS
CCAP ^9^ | % received appropriate anti-panic medication | | All months (through 12 months) | | NS
Process of Care/Program Use
CCAP ^9^ | % received ≥3 counseling sessions plus at least 4 of 7 CBT techniques | | 3 months | Intervention | P<.001 | Highest proportion was 63% of intervention group at 3 months
CCAP ^9^ | % received ≥3 counseling sessions plus at least 4 of 7 CBT techniques | | 6 months | Intervention | P=.005 | Highest proportion was 63% of intervention group at 3 months
CCAP ^9^ | % received ≥3 counseling sessions plus at least 4 of 7 CBT techniques | | 9 months | | NS | Highest proportion was 63% of intervention group at 3 months
CCAP ^9^ | 12 months | Intervention | P=.02
CCAP ^9^ | % received any anti-panic medication | | 3 months | | NS
CCAP ^9^ | % received any anti-panic medication | | 6 months | | NS
CCAP ^9^ | % received any anti-panic medication | | 9 months | | NS
CCAP ^9^ | 12 months | | NS
CCAP ^9^ | % received any counseling | | 3 months | Intervention | P<.001 | Highest proportion was 70% of intervention group at 3 months
CCAP ^9^ | % received any counseling | | 6 months | Intervention | P=.05 | Highest proportion was 70% of intervention group at 3 months
CCAP ^9^ | % received any counseling | | 9 months | Intervention | P=.004 | Highest proportion was 70% of intervention group at 3 months
12 months | Intervention | P<.001
Rollman, 2005 ^101^ | % on medication | | 12 months | Intervention | 23.9, 95% CI 7.1; 41.8, p=.006 | NS at 4, 8, and 12 months
% with mental health specialty visit | | 12 months | | NS | 18% in intervention vs. 26% in control
Satisfaction with Treatment
Roy-Byrne, 2001 ^109^ | Satisfaction with treatment | | 12 months | Intervention | P=.039
Price, 2000 ^91^ | Satisfaction with anxiety treatment | | 6 months | Intervention | P<.0001 | 10 of 11 satisfaction items significant
OTHER DISORDERS
Titration Trials
Epstein, 2007 ^112^ | Improvement in % physicians using titration trials | | 12 months | Intervention | Beta -.283, SE 0.09, p<.01 | Collaborative care physicians increased from 9% to 68%, compared to no increase in control group
Medication Management
Epstein, 2007 ^112^ | Improvement in % physicians systematic monitoring medication | | 12 months | | NS | Both groups increased. 36% of collaborative care group did not monitor

Systematic screening and case identification. Currently, one of the more readily applicable uses of health IT is for systematic screening and case identification. For example, current guidelines recommend screening for depression during primary care visits, especially for practices that have systems in place to ensure that communication of screening results is coordinated with followup and treatment. ^164^ Several depression screening instruments are available, such as PRIME-MD, GHQ, and the PHQ9. Several of the studies of depression care in this review reported utilizing a screening questionnaire to identify subjects with depression, but only a few reported using health IT to communicate a positive screen to providers. For instance, in the study by Fortney et al., the results for depression screening were entered into a common, shared EHR via an electronic progress note and the primary care provider was notified of the positive results by being designated as an additional signer on the electronic progress note. ^131^ Similarly, Rollman et al. screened patients for anxiety disorders using PRIME-MD and positive screens were communicated to the PCP by generating an interactive e-mail alert (flag) through a common, shared EHR system and an electronic letter to the PCP. ^101^

An efficient and powerful tool for health IT is to identify potential cases and develop “electronic registries” of the target population by using existing computerized pharmacy and electronic health record databases. For example, Simon et al. successfully identified patients with depression by electronically searching computerized pharmacy and visiting registration databases for all new episodes of anti-depressant medications. ^84^ Fortney et al. successfully identified cases of depression using administrative data available from annual depression screening results that had been previously entered into the EHR. ^131^

Communication between primary care and specialty mental health providers. With the advent of the electronic health record, it is increasingly possible for primary care and specialty mental health providers to share medical records, which traditionally are separate. The promise of shared medical records is in the ability to foster communication between providers, which in turn would facilitate collaboration, and provide decision support to primary care providers. We identified several studies in which integration programs capitalized on the availability of shared EHRs to facilitate communication between PCPs and mental health specialty providers both on-site and off-site. For example, Hedrick et al. fostered collaborative care in the VA by using electronic progress notes to communicate patient clinical information and treatment recommendations between psychiatrists and PCPs. ^87^ Providers were notified about the progress note by provider alert and co-signature functions that are part of VA EHR system. Adler et al. in a pharmacist driven intervention to improve antidepressant medication utilization, used a standard computerized template that enabled the pharmacist to easily communicate specific information on patient antidepressant use to their PCP. ^106^

Decision support. The uses of health IT to meet the information needs of PCPs and provide support for treatment decisions for psychiatric disorders include simple notification of the diagnosis of a psychiatric disorder, as previously described, as well as provider education, guideline-based treatment recommendations, and formal telepsychiatric consultation. Technologies include interactive video conferencing technology and the internet or intranet. For example, in the TEAM intervention, ^131^ 1-hour continuing medical education presentations on managing depression in primary care were delivered to off-site PCPs via interactive video and PCPs were informed about the TEAM website, which contained a link to the MacArthur Foundation Depression Tool Kit. Formal telepsychiatric consultation, using interactive video equipment, was available to off-site PCPs who did not have on-site psychiatrists but was rarely utilized. Rollman et al. developed an intranet website that could be accessed from the EHR that offered detailed advice for treatment of depression based on the AHRQ depression treatment guideline. ^165^ In sum, we identified few studies reporting on use of health IT for decision support, indicating that this area is underdeveloped and understudied. We have minimal knowledge on how best to utilize health IT to provide decision support for psychiatric treatment decisions in primary care.

Monitoring of clinical status and medication adherence. The use of health IT for clinical status monitoring for symptoms such as depression and anxiety appears to be quite effective in providing clinicians and study teams with up-to-date information about patients' clinical status. For example, monitoring PHQ9 scores or similar measures were employed in studies of depression care. Several patient specific tracking methods have been employed and include web-based tracking systems, Microsoft Access based electronic database, hand-held organizers (e.g., PDAs), and simple documentation of clinical status in the EHR so it is easily available to clinicians. A web-based tracking system was used by several of the larger studies of depression care, including the IMPACT intervention.

Few studies appear to be using health IT to improve monitoring for medication adherence. In the literature we observed two methods employed for monitoring medication adherence that involved health IT: (1) use of a telephone care manager who would speak to the patient and obtain the medication use history and, if available, document the medication history in the EHR, and (2) surveillance of automated pharmacy databases for continued refills of medications.

Treatment delivery. The literature was very sparse on the use of health IT for psychiatric treatment delivery and appears to mainly involve telemedicine technologies. Telemedicine improves access to care, especially for patients in rural areas, and allows for patients to receive psychiatric care without an in-person encounter. Types of telemedicine that were reported included telephone psychiatric consultation, telephone case management, and telephone psychotherapy. We did identify one study of computer delivered CBT for anxiety management. In this study, an anxiety specialist and the patient used a stand-alone computer together and the anxiety specialist directed the patient through a computerized CBT session. ^7^ In sum, telemedicine and health IT hold great promise for improving access and for delivering psychiatric treatment, but currently remain, for the most part, untested.

### Key Question 5: What Financial and/or Reimbursement Structure was Employed in Successful Integration Programs? Is there Evidence to Suggest that any Specific Financial/Reimbursement Strategy is Superior to Another?

One of the largest challenges to integrated care programs is funding. Reimbursement for provider-to-provider communication, the basis of integrated care, is not allowed under Medicaid law. ^150^ This effect is magnified since a large proportion of patients with mental illness are covered by Medicaid. ^26^ Similarly, the disincentives built into the fee for service, carve-out, and capitation arrangements affect the general insured populations. ^151^ The difficulties with billing and being reimbursed for communication and coordination activities generally performed by care managers or therapists with additional care management responsibilities, and the supervision of the care managers by psychiatrists, in integrated care programs compounds the problem.

Bachman et al. provides an excellent discussion of possible reimbursement structures for depression care management. ^149^ The authors describe seven methods of paying for care management, varying by the location of the care manager (see Figure 13), including (1) practice-based care management on a fee-for-service basis, (2) practice-based care management under contract to health plans, (3) global capitation, (4) flexible infrastructure support for chronic care management, including pay for performance, (5) health-plan-based care management, (6) third-party-based care management under contract to health plans, and (7) hybrid models. Pay for performance is one of the most recent reimbursement inventions suggested to boost health care quality and has started receiving attention for behavioral health. ^166^ However, pay for performance is worrisome to community health providers who service historically underserved patients, many of whom often are complex patients with multiple conditions. ^150^

Figure 13. Methods for paying for care management (from Bachman et al., 2006) ^149^

While there were a number of effectiveness trials for depression that recruited patients from essentially all major provider settings and representing all forms of insured/not insured, no trial reported specifics of reimbursement structures beyond baseline information, nor were results analyzed by type of reimbursement program. Certainly there is currently no evidence to support the effects of one payment strategy over another in terms of outcomes. The literature remains descriptive, providing only occasional brief case reports of individual initiatives that include some information on reimbursement structures. ^167,^ ^168^ ^169,^ ^170^

A new SAMHSA report provides the most comprehensive information to date on public insurance reimbursement structures and the associated barriers to implementing integrated care. ^14^ The report outlined Medicaid and Medicare reimbursement structures and policies that create financial disincentives for integrated care. Medicaid includes such problems as restrictions on same-day billing for primary care and mental health providers, carve-outs for managed care that favor one type of provider over another, reimbursement difficulties for specific components of integrated care programs such as care managers, activities necessary for collaborative care and team approaches such as provider-to-provider communication, and telemedicine for remote and underserved areas. Medicare also has numerous reimbursement issues, such as limiting outpatient mental health treatment to 62.5 percent of costs, unresolved problems with procedure codes, and restrictions imposed by medical review policies. The report concluded with a summary of an expert forum whose task it was to identify additional barriers that affect reimbursement, prioritize the barriers, and suggest future actions. The top barriers related to primary care settings were:

- State Medicaid restrictions on payments for same-day billing.
- Lack of reimbursement for collaborative care and case management related to mental health services.
- Lack of reimbursement of service provided by nonphysicians, alternate practitioners, and contract practitioners.
- Medicaid disallowance of reimbursement when primary care providers submit bills listing only a mental health diagnosis and corresponding treatment.
- Reimbursement rates in rural and urban settings.
- Lack of reimbursement incentives for screening and providing preventive mental health services.

The recommendations for alleviating the barriers for these items were to:

- Reduce denials associated with same-day billing, such as mental health and physical health services when services are provided on the same day by two separate practitioners.
- Improve reimbursement of evidence-based practices, collaborative care, team approaches to providing care, and reimbursement of care and case management services.
- Increase payment for professional services by nonphysician practitioners under Medicaid and Medicare.
- Improve primary care provider access to mental health services reimbursed through carve-outs.
- Increase reimbursement rates in urban and rural settings.
- Improve incentives for screening and prevention.
- Recommend a collaborative effort across the Department of Health and Human Services (DHHS) agencies, including CMS, HRSA, SAMHSA, and AHRQ to clarify and coordinate reimbursement policies.

## Methods of Integrating Primary Care into Specialty Mental Health

The search of the literature returned only three trials, ^16,^ ^17,^ ^171^ all of which have been included in a previous systematic review of six trials designed to improve general medical care in people with mental addictive disorders. ^15^ As the quality of the narrative review was deemed good and shared a similar aim, we did not re-abstract the three trials. We did not include in the results below the two trials that took place in inpatient settings or the trial with a methadone clinic setting.

### Key Question 1. What Models have been Used? What is the Evidence that Integrated Care Leads to Better Outcomes?

Druss and von Esenwein's review found all three outpatient setting trials used “collaborative care” models. ^15^ These models demonstrated intermediate to high levels of involvement by primary care providers, with regular contact between medical and mental health staff. Such staff may or may not be co-located.

Two of the trials showed improvement in primary care linkages ^16^ or substantially higher number of annual primary care visits in the intervention groups. ^171^ Medical quality improved for intervention patients vs. control patients in the two studies that reported quality of care. Druss et al. reported significant improvement in 15 of 17 guideline-recommended preventive activities. ^16^ Weisner et al. found increased diagnosis rates for four common medical conditions. ^17^

Patient outcomes also improved. Druss et al. found improvements in both the SF36 Physical Component Scale and the Mental Component Scale for intervention patients, ^16^ while Willenbring and Olson reported improvements in physical wellbeing. ^171^ Further, Willenbring and Olson reported improvements in mortality rates for the intervention group in bivariate analysis, although a Cox survival analysis was underpowered and nonsignificant. ^171^ Additionally, both studies that addressed alcoholic addiction disorders found improved abstinence rates in the groups receiving integrated care. ^17,^ ^171^

Two of studies reported in the Druss and von Esenwein review formally assessed program costs. ^16,^ ^17^ The studies measured intervention costs based on staff salaries and activities. The programs were found to be cost-neutral as increases in outpatient expenditures were offset by declines in inpatient and emergency room use. The review also reported a significant decline in annual costs for the subsample of patients in the Weisner et al. trial with substance-related mental and medical comorbidities, compared to the control group. ^18^

### Key Question 2. To What Extent Does the Impact of Integrated Care Programs on Outcomes Vary for Different Populations?

The trials reported in the Druss and von Esenwein review ^15^ were for adults with serious mental health or substance abuse disorders. The literature is silent on differences in patient outcomes for age, gender, or ethnicity, although the studies were not restricted by gender or ethnicity.

### Key Question 3. What are the Identified Barriers to Successful Integration? How were Barriers Overcome? What are the Barriers to Sustainability?

The three trials took place in large, integrated health systems. Two were conducted at the VA while the third was conducted in a large Health Maintenance Organization (HMO) in California. The VA's structure is conducive to integrated care as medical and mental health care are generally co-located in the large VA medical centers. Large HMOs also have an advantage of integrated systems with medical and mental health care available within the system. Integration of primary health care into free-standing community substance use disorder treatment clinics with no immediate access to medical health care facilities would likely present several additional barriers and challenges not encountered in the VA and HMO trials.

More generalizable examples of barriers to providing primary care in specialty mental health care is provided in a report of a performance improvement project at the Health & Education Services, Salem, Massachusetts, of the Northeast Health System, a large community-based health care delivery system, for a population of individuals receiving outpatient mental health services. ^172^ The clinic implemented an integrated care program based on the Druss et al. trial. ^16^ The clinic did not anticipate the complexities involved in setting up and running a functional primary care space within a behavioral health care setting, including the procurement of items such as adequate lighting, privacy screens, and changing areas. Nor did they anticipate the discomfort the presence of items such as gynecological examination tables would induce. There were complaints of losing prime office space to the primary care function. Laboratory personnel forgot items outside of established routine practices, such as hematology samples left by the primary care nurse for pickup. General behavioral medicine staff became more supportive of the change to providing primary care by gaining familiarity with the engaging primary care staff and the positive responses from the patients.

### Key Question 4. To What Extent did Successful Integration Programs Make Use of Health IT?

The only reported use of health IT was by Druss and colleagues, who noted the use of common medical records and email for communication. ^16^ Presumably the Willenbring et al. trial also benefited from the same IT available in VA centers. ^171^

### Key Question 5. What Financial and/or Reimbursement Structure was Employed in Successful Integration Programs? Is there Evidence to Suggest that any Specific Financial/Reimbursement Strategy is Superior to Another?

As mentioned above, the trials took place in large, integrated health systems. The authors of one study suggested that since positive results were found in the sub-population with substance abuse related medical conditions, high levels of integration may not be necessary or appropriate for all patients. ^17^ Given the minimal cost savings, a sufficiently large caseload to support medical practice may be the most critical concern for providers who are not part of a large system that assesses costs from a health plan perspective. Boardman reported the performance improvement project received grants from Blue Cross Blue Shield of Massachusetts Foundation for calendar years 2004 and 2005 to help meet program costs. ^172^ Funding remains an ongoing issue while the program works to maximize insurance reimbursement.