# Acknowledgments

We would like to thank Li Tao for assistance with the literature search and data abstraction; Tatyana Shamliyan, M.D., M.S., for her assistance with data analysis; Rebecca Schultz for her help with editing and formatting this report; and especially Marilyn Eells for her editing, formatting, and organizational skills, and her professionalism.

Thanks also to Macaran Baird, M.D., M.S., Benjamin Druss, M.D., M.P.H., Wayne Katon, M.D., David Mechanic, Ph.D., Harold Pincus, M.D., Lisa Rubenstein, M.D., M.S.H.S., Herbert Schulberg, Ph.D., John Williams, M.D., M.H.S., and the staff at NAMI, who reviewed a draft of the document, for their time and the suggestions and comments that improved the quality of the report.

We would also like to thank the staff at the following organizations who so generously gave of their time to help coordinate and complete the case studies:

- AETNA
- Hartford, CT
- www.aetna.com

- The DIAMOND Initiative
- Minneapolis, MN
- www.icsi.org

- Group Health Cooperative
- Seattle, WA
- www.ghc.org

- Northern California Kaiser Permanente
- San Francisco, CA
- www.kpcmi.org

- RESPECT-Depression
- www.depression-primarycare.org

- Veterans Administration
- www.hsrd.research.va.gov/queri/

- CorpHealth
- Fort Worth, TX
- www.corphealth.com

- Eastern Band of Cherokee Health
- Cherokee, NC
- www.nc-cherokee.com

- Intermountain Healthcare
- Salt Lake City, Utah
- http://intermountainhealthcare.org/xp/public/

- MaineHealth
- Portland, ME
- http://www.mmc.org/mh_homepage.cfm

- Cherokee Health of Tennessee
- Knoxville, TN
- www.cherokeehealth.com

- Washtenaw County Health Organization
- Ypsilanti, MI
- http://www.ewashtenaw.org/government/departments/wcho