# Preface

The Agency for Healthcare Research and Quality (AHRQ), through its Evidence-based Practice Centers (EPCs), sponsors the development of evidence reports and technology assessments to assist public- and private-sector organizations in their efforts to improve the quality of health care in the United States. This report was requested and funded by AHRQ; the Health Resources and Services Administration; Substance Abuse and Mental Health Services Administration, Center for Mental Health Services, Center for Substance Abuse Treatment; as well as the Office of Women's Health and the Office of Minority Health at the Department of Health and Human Services. The reports and assessments provide organizations with comprehensive, science-based information on common, costly medical conditions, and new health care technologies. The EPCs systematically review the relevant scientific literature on topics assigned to them by AHRQ and conduct additional analyses when appropriate prior to developing their reports and assessments.

To bring the broadest range of experts into the development of evidence reports and health technology assessments, AHRQ encourages the EPCs to form partnerships and enter into collaborations with other medical and research organizations. The EPCs work with these partner organizations to ensure that the evidence reports and technology assessments they produce will become building blocks for health care quality improvement projects throughout the Nation. The reports undergo peer review prior to their release.

AHRQ expects that the EPC evidence reports and technology assessments will inform individual health plans, providers, and purchasers as well as the health care system as a whole by providing important information to help improve health care quality.

We welcome written comments on this evidence report. They may be sent to the Task Order Officer named below at: Agency for Healthcare Research and Quality, 540 Gaither Road, Rockville, MD 20850, or by email to epc@ahrq.gov.

- Carolyn M. Clancy, M.D.
- Director
- Agency for Healthcare Research and Quality

- Beth A. Collins Sharp, R.N., Ph.D.
- Director, EPC Program
- Agency for Healthcare Research and Quality

- Elizabeth M. Duke, Ph.D.
- Administrator
- Health Resources and Services Administration

- H. Westley Clark, M.D, J.D., M.P.H., C.A.S., F.A.S.A.M.
- Director, Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration

- Wanda K. Jones, Dr.P.H.
- Deputy Assistant Secretary for Health
- Office of Women's Health
- Office of the Secretary
- Department of Health and Human Services

- Jean Slutsky, P.A., M.S.P.H.
- Director, Center for Outcomes and Evidence
- Agency for Healthcare Research and Quality

- Charlotte Mullican, M.P.H.
- EPC Program Task Order Officer
- Senior Advisor for Mental Health Research
- Agency for Healthcare Research and Quality

- A. Kathryn Power, M.Ed.
- Director, Center for Mental Health Services
- Substance Abuse and Mental Health Services Administration

- Garth Graham, M.D., M.P.H.
- Deputy Assistant Secretary for Minority Health
- Office of Minority Health
- Office of the Secretary
- Department of Health and Human Services