# List of Acronyms/Abbreviations

- | negative; without
? | unknown; unclear
+ | positive; with
+/- | with or without
→ | followed by
↓ | Decrease
Δ | Change
A | doxorubicin (Adriamycin®)
AACC | American Association for Clinical Chemistry
AC | doxorubicin (Adriamycin®)/cyclophosphamide
AI | aromatase inhibitor
ANA | Anastrozole
ASCO/CAP | American Society of Clinical Oncology
BAC | bronchioalveolar adenocarcinoma
CAF | cyclophosphamide, doxorubicin (Adriamycin®) and fluorouracil
CALGB | Cancer and Leukemia Group B
CAP | College of American Pathologists
cCR | clinical complete response
CEF | cyclophosphamide plus epirubicin plus fluorouracil
CEP17 | chromosome 17 centromere
ChiSq | chi square
CHT | Chemotherapy
CI | confidence interval
CISH | chromogenic in-situ hybridization
Cisplat | Cisplatin
CMF | cyclophosphamide plus methotrexate plus fluorouracil
cPR | clinical partial response
CR | complete response
cSD | clinical stable disease
Cx | Control
D | Docetaxel
DAC | docetaxel plus doxorubicin (Adriamycin®)/cyclophosphamide
DES | Diethylstilbestrol
DFS | disease-free survival
DNA | deoxyribonucleic acid
Disom | Disomy
Docetax | Docetaxel
Doxorub | Doxorubicin
E | Epirubicin
Ea | Each
EBRT | external-beam radiation therapy
EC | epirubicin/cyclophosphamide
ECD | extracellular domain
ECOG | Eastern Cooperative Oncology Group
EGF | epidermal growth factor
ELISA | enzyme-linked immunosorbent assay
Epirub | Epirubicin
ER | estrogen receptor
ERD | extensive residual disease
ET | epirubicin/paclitaxel (Taxol®)
FAC | fluorouracil plus doxorubicin (Adriamycin®)/cyclophosphamide
FDA | U.S. Food and Drug Administration
FE | fixed effects
FEC14 | cyclophosphamide plus epirubicin plus fluorouracil every 14 days
FEC21 | cyclophosphamide plus epirubicin plus fluorouracil every 21 days
FISH | fluorescence in-situ hybridization
Grp | Group
HDC/AuSCS | high-dose chemotherapy with autologous stem-cell support
HER | human epidermal growth factor receptor
HR | hazard ratio
IAUC | International Union Against Cancer
IHC | Immunohistochemistry
ISH | in-situ hybridization
IV | Intravenous
KPS | Karnofsky Performance Score
K-M | Kaplan-Meyer
KQ | Key Question
LABC | locally advanced breast cancer
LET | Letrozole
LH-RH | luteinizing hormone releasing hormone
LN | lymph node
log regr | log regression
LR | log-rank; likelihood ratio
MAb | monoclonal antibody
MBC | metastatic breast cancer
Med | Median
MH | Mantel-Hantzel
Mn | Mean
Mos | Months
MRD | minimal residual disease
MTX | Methotrexate
MV | Multivariate
N | Number
N | Node
N | No
NA | not applicable
NCCN | National Comprehensive Cancer Network
NCCTG | North Central Cancer Treatment Group
NE | not evaluable
Neg | Negative
NR | not reported
NS | not significant
NSABP | National Surgical Adjuvant Breast and Bowel Project
NSCLC | non-small cell lung cancer
OC | ovarian cancer
ORR | overall response rate
OS | overall survival
P | Paclitaxel
Paclit | Paclitaxel
PCR | polymerase chain reaction
PD | progressive disease
PE | cisplatin/etoposide
Polysom | Polysomy
Pos | Positive
Post | Postmenopausal
Postmen | Postmenopausal
PR | progesterone receptor; partial response
Pre | Premenopausal
Premen | Premenopausal
PRO | Prospective
Progr | Progression
Prop | proportional; proportion
pt(s) | patient(s)
q wk | Weekly
q2wk | every 2 weeks
q3wk | every 3 weeks
RCT | randomized controlled trial
Resp | Response
RFI | recurrence-free interval
RFS | recurrence-free survival
Rng | Range
RR | relative risk
RT | radiation therapy
S | Serum
SABCS | San Antonio Breast Cancer Symposium
SCC | squamous cell carcinoma
sd, SD | standard deviation
SD | stable disease
SE | standard error
SERM | selective estrogen receptor modulators
SGA | subgroup analysis
sHER2 | serum HER2
SISH | silver in-situ hybridization
SWOG | Southwest Oncology Group
T, t | tumor, tissue
TAC | paclitaxel (Taxol®) plus doxorubicin (Adriamycin®)/cyclophosphamide
TAM | Tamoxifen
tHER2 | tissue HER2
TRZ | Trastuzumab
TTF | time to failure
TTP | time to progression
Tx | Treatment
Unk | Unknown
US | United States
UV | Univariate
W-G | Wilcoxon-Gehan test
WHO | World Health Organization
Y | Yes
Yo | years old
yr(s) | year(s)