# Executive Summary

The human epidermal growth factor receptor-2 (HER2) gene is amplified and the HER2 protein overexpressed in approximately 18–20 percent of breast cancer cases. Amplification or overexpression of HER2 is associated with poor prognosis. Evidence from randomized trials demonstrates that adding trastuzumab, a therapeutic monoclonal antibody that targets HER2, to adjuvant chemotherapy regimens for HER2-positive breast cancer improves survival. HER2 also is overexpressed in other epithelial malignancies such as ovarian, thyroid, lung, salivary gland/head and neck, stomach, colon, and prostate cancers.

This report is a systematic review of the evidence on other applications of HER2 testing to the management of cancer patients including: potential for response to trastuzumab among breast cancer patients who have negative, equivocal, or discordant HER2 assay results; use of HER2 assay results to guide selection of breast cancer treatments other than trastuzumab (i.e., chemotherapy regimen or hormonal therapy regimen); the use of serum HER2 to monitor treatment response or disease progression in breast cancer patients; and use of HER2 testing to manage patients with ovarian, lung, prostate, or head and neck tumors. The concordance and discrepancy of HER2 measurement methods are discussed in a narrative review.

## Methods

The review methods were defined prospectively in a written protocol. A technical expert panel provided consultation. The draft report was also reviewed by other experts and stakeholders.

A narrative review was conducted on Key Question 1, which addressed concordance and discrepancy among HER2 assays in breast cancer. HER2 assay results are influenced by multiple biologic, technical, and performance factors. Since many aspects of HER2 assays were standardized only recently, we could not isolate effects of these disparate influences on assay results and patient classification. This challenged the validity of using systematic review methods to compare available assay technologies.

For Key Questions 2–5, we sought randomized trials or single-arm series (prospective or retrospective) of identically treated patients that presented relevant outcome data associated with HER2 status. Primary outcomes were: overall survival (OS); disease-free survival (DFS); progression-free survival (PFS); time to failure (TTF) or progression; quality of life; palliation of symptoms; and treatment-related adverse effects.

Our search had no language restrictions and used these electronic databases:

- MEDLINE® (through February 2007)
- EMBASE® (through February 2007)
- Cochrane Controlled Trials Register (through February 2007)

The searches were updated in April 2008, using the Cochrane clinical trial filter.

Additional sources were the past two years of conference proceedings of the American Association for Clinical Chemistry (AACC), American Society of Clinical Oncology (ASCO), College of American Pathologists (CAP), and the San Antonio Breast Cancer Symposium (SABCS).

Of 6,337 citations, 666 articles were retrieved and 70 were selected for inclusion:

- Three articles plus one abstract on use of trastuzumab among HER2-negative or -discordant breast cancer patients;
- 26 articles on chemotherapy or hormonal therapy for breast cancer patients;
- 15 articles on plasma or serum HER2 in patients treated for breast cancer; and
- 26 articles on serum or tissue HER2 in patients with lung cancer, ovarian cancer, head and neck cancer, and prostate cancer.

A single reviewer screened citations for article retrieval; citations judged as “uncertain” were reviewed by a second reviewer. The same procedure was used to select articles for inclusion in the review. A single reviewer performed data abstraction and a second reviewed the evidence tables for accuracy. However, study quality was appraised by dual independent review. All disagreements were resolved by consensus.

The quality of predictive studies was assessed using the general approach described in the “Reporting Recommendations for Tumor Marker Prognostic Studies” (REMARK) statement (McShane, Altman, Sauerbrei, et al., 2005). In addition, we used a hierarchical framework for evaluating how informative different designs and analytic strategies would be to predictions of outcomes according to HER2 status. Most informative is a trial that randomizes patients to receive treatment guided by HER2 results or not; or, alternatively, a trial that stratifies randomized assignment to treatment groups by HER2 status (Conley and Taube, 2004). Other types of studies, in decreasing order of information value, include: randomized trials using prespecified multivariate subgroup analyses, randomized trials using post-hoc multivariate subgroup analyses, randomized trials presenting HER2 by treatment subgroup analyses, single-arm studies using prespecified multivariate analyses, single-arm studies using post-hoc multivariate analyses, and single-arm studies using univariate analyses.

## Results

### Key Question 1: Concordance and Discrepancy of HER2 Methods

HER2 assay results are influenced by multiple biologic, technical and performance factors. Since many aspects of HER2 assays were standardized only recently, these disparate influences confound the existing literature that compares results of different methods. Discordances between immunohistochemistry (IHC) and fluorescent in situ hybridization (FISH) results might arise in one of three ways. They may be artifacts of one accurate and one inaccurate test or of two inaccurate tests, as preanalytic, analytic, and postanalytic practices can vary among laboratories within a study, as well as among studies. Interobserver variability can play a role. Alternatively, discordances may reflect a threshold issue, either related to changes in threshold definitions over time, or an inherent problem of using a continuous measure to classify patients dichotomously. Finally, discordant test results might accurately reflect a variation among patients with respect to the biologic mechanisms that can increase membrane levels of the HER2 protein. This clearly affects the interpretation of evidence on the use of “HER2 status” to predict treatment or disease outcomes, which presumes accurate classification by tissue assays.

Notably, there is no recognized gold standard to determine the HER2 status of tumor tissue, which also precludes consensus on one “best” HER2 assay. Recent guidelines acknowledge present uncertainty, permit clinicians and laboratories to choose an initial well-validated and properly performed HER2 assay method, and recommend confirming results with an alternative assay when initial tests are equivocal. The ASCO/CAP expert panel (Wolff, Hammond, Schwartz, et al., 2007a) defines equivocal HER2 assay results as IHC 2+, or HER2 gene copy number from 4.0 to 6.0, or HER2/CEP17 ratio from 1.8 to 2.2, if ISH is the first or only assay.

### Key Question 2: HER2-Negative or -Discrepant Breast Cancer

Currently available evidence on outcomes of trastuzumab added to chemotherapy for most HER2-equivocal, -discordant, or -negative patients may generate hypotheses, but is too weak to test hypotheses. Most of this evidence is from post-hoc analyses on subgroups not directly randomized or stratified by HER2 status. Scant but intriguing evidence suggests the hypothesis that some patients currently classified as HER2 negative may benefit from adjuvant trastuzumab. Data reported from a post-hoc subgroup analysis of one adjuvant trial (NSABP B31) showed significantly longer DFS and relapse-free interval (RFI) in FISH-negative IHC ≤2+ patients given trastuzumab than in patients managed without trastuzumab, whether the analysis did or did not include those who were IHC 0. However, analysis of data from another similar adjuvant trial (NCCTG N9831) found no significant differences. Both were interim analyses of trials in which fewer than 25 percent of subjects had reached a failure event. Followup analyses from these trials will be of interest.

CALGB 9840 investigators also analyzed a subgroup of metastatic FISH-negative patients that either had (n=38) or did not have (n=103) polysomy 17; overall response rate (ORR) was significantly higher with versus without trastuzumab for those with polysomy 17, but was identical with or without trastuzumab for those without polysomy 17. However, a study in the adjuvant setting (Reinholz, Jenkins, Hillman, et al., 2007) reports no impact of polysomy 17 on benefit from trastuzumab. Additionally, other studies report conflicting data on association of polysomy 17 with overexpression of HER2 protein.

### Key Question 3: Breast Cancer Patients Receiving Chemotherapy (3a) or Hormonal Therapy (3b)

For Question 3a, across all three treatment settings (adjuvant, neoadjuvant, or advanced/metastatic), currently available evidence comparing chemotherapy outcomes in HER2-positive and HER2-negative patient subgroups may generate hypotheses, but is too weak to test hypotheses. In the only study that prespecified multivariate subgroup analysis by HER2 status, interaction of assigned adjuvant treatment (with or without paclitaxel) with HER2 status to predict outcome was not statistically significant (ratio of hazard ratios [HRs]=0.85; p=.41). All other evidence is from post-hoc analyses on subgroups not directly randomized, selected, or stratified by HER2 status, and used data from secondary or correlative analysis on patient subgroups with archived tissue samples. It is uncertain whether these subgroups were well balanced. No studies for Question 3a used trastuzumab for HER2-positive patients.

Available evidence focuses on three types of adjuvant chemotherapy: cyclophosphamide plus methotrexate plus fluorouracil (CMF), regimens with an anthracycline, and paclitaxel after or with doxorubicin (Adriamycin®) plus cyclophosphamide (AC). Evidence from two studies (one randomized, controlled trial and one series) suggests HER2-positive patients may benefit less from CMF (smaller improvements in OS and DFS) than HER2-negative patients. Only one of four randomized, controlled trials reports a statistically significant interaction that suggests HER2-positive patients (but not HER2-negative patients) benefit from including an anthracycline in their treatment regimen. Given the highly statistically significant result favoring anthracycline therapy for the entire population (N=14,000) of breast cancer patients included in the Early Breast Cancer Trialists' Collaborative Group (EBCTCG 2005) patient-level meta-analysis, a rigorous test of this hypothesis is necessary before one can conclude that omitting anthracyclines from adjuvant chemotherapy regimens would not worsen outcome for HER2-negative patients.

Two trials compared different doses or frequencies of anthracycline-based regimens. One reported statistically significant interaction of cyclophosphamide, doxorubicin, and fluorouracil (CAF) dose with HER2 status to predict treatment outcome, but the second showed no relationship. One study found that adding paclitaxel after AC improves OS and DFS for HER2-positive patients, but may not improve these outcomes for HER2-negative patients. In contrast, the only randomized, controlled trial with a prespecified multivariate subgroup analysis found no difference by HER2 status in outcomes of concurrently added paclitaxel. Thus, for each of the adjuvant chemotherapy regimens compared, available evidence is too weak to rule out the possibility that HER2-negative patients may benefit from using the added drug or higher dose.

Evidence on whether HER2 status predicts complete response (pCR) to neoadjuvant chemotherapy is limited to four uncontrolled series (retrospective analysis in three). Data are lacking to directly compare any neoadjuvant regimens. There is also limited evidence on differences by HER2 status for outcomes of chemotherapy for advanced or metastatic disease, with most studies lacking statistical power.

For Question 3b, four studies addressed use of tamoxifen in various breast cancer patient populations, and two compared tamoxifen with aromatase inhibitors. None of these studies included trastuzumab. There were no trials that stratified randomization by HER2 status or randomization to therapy directed by HER2 results or not. Less informative designs were used, including post-hoc multivariate analyses in five randomized trials and one post-hoc multivariate analysis in a single-arm study. Data are too weak to reach new conclusions about differences between subgroups based on HER2 status in effects of specific hormone therapies for patients who are hormone-receptor positive.

### Key Question 4: Plasma or Serum HER2 (sHER2) in Patients Treated for Breast Cancer

Of 13 included studies, three were randomized trials and 11 were single-arm designs. The evidence is weak on whether sHER2 predicts outcome after treatment with any regimens in any setting. Evidence primarily focused on first-line or second- and subsequent-line treatment of metastatic disease using variety of regimens. Studies used different thresholds for a positive sHER2 result and varied on whether patient selection required positive tissue HER2 status. One randomized and two single-arm studies performed multivariate analysis, although reporting lacked sufficient detail. Univariate analyses provide very limited information value, suggesting candidate variables for future multivariate analyses. Overall, the evidence is too weak to assess whether sHER2 predicts disease progression, treatment response, or outcomes of any specific treatment regimen.

### Key Question 5. Serum or Tissue HER2 Testing in Malignancies of Lung, Ovary, Head and Neck, or Prostate

With respect to use of serum or tissue HER2 testing for malignancies of lung, ovary, head and neck, or prostate, the evidence is quite weak. Studies were heterogeneous regarding treatment regimens and thresholds for positive HER2 test results. Of 22 studies addressed for the four types of malignancies, there were no randomized trials that could have analyzed HER2 by treatment effect interactions. Six multivariate analyses in single-arm designs were performed, all of which were poorly described; it is unclear if they were well conducted. Data from these exploratory analyses did not consistently find that HER2 status predicts treatment results. Univariate analyses provide very limited information value, at best suggesting candidate variables for future multivariate analyses.

## Discussion and Future Research

Overall, few trials directly investigated the key questions of this systematic review. Going forward, cancer therapy trial protocols should incorporate elements to facilitate robust analyses of the potential of HER2 to improve treatment management. These elements include:

- Detailed reporting of how HER2 status was ascertained.
- Stratified randomization by HER2 status or prospectively specified HER2 subgroup analysis of outcomes.
- Detailed recording of relevant data and archiving of tissue samples for all participants, and accessible to other researchers, to permit future subgroup analyses of outcomes by HER2 status.

The rationale is strongest for breast cancer therapy trials, as many therapeutic agents, classes, and regimens have been and will be tested. This approach can be generalized to other tumors, to promising biomarkers other than HER2, and to serial collection of serum samples for sHER2 levels. Maximizing data collection in trials planned for other purposes offers an opportunity to screen for potential applications of HER2 and other biomarkers.

For Key Question 2, potential for response to trastuzumab among breast cancer patients who have equivocal, discordant, or negative HER2 assay results, evidence is scant but intriguing. Whether other markers might predict response to trastuzumab for these subgroups could be explored using tissue samples from completed trials.

For Key Question 3, the most compelling question is whether anthracyclines benefit HER2-negative patients. A pragmatic approach for future research is to use individual patient data, of the Early Breast Cancer Trialists' Collaborative Group (EBCTCG) meta-analysis, which compared survival with anthracyclines versus CMF in 14,000 patients. However, this approach may be limited by availability of sufficient tumor samples. Also of interest is evidence to clarify whether aromatase inhibitors are more effective than tamoxifen in HER2-positive patients.

For Key Questions 4 and 5, evidence does not support conclusions about use of serum HER2 for any treatment setting within breast cancer or about any use of serum or tissue HER2 for cancer of the lung, ovary, head and neck, or prostate. Future exploratory studies in these areas using preserved or prospectively collectively specimens should be designed with attention to study quality concerns.

## Conclusions

Since many technical and performance aspects of HER2 assays were not standardized until very recently, differences in preanalytic, analytic, and postanalytic practices confound the existing literature. Available evidence supports hypotheses generation but is too weak to test hypotheses. Scant but intriguing evidence suggests the hypothesis that some patients currently classified as HER2 negative may benefit from adjuvant trastuzumab. Future research should focus on biomarkers that might select such patients. Evidence suggests HER2-positive, but not HER2-negative, patients may benefit from chemotherapy regimens with an anthracycline; but rigorous testing of this hypothesis is necessary. Also worth additional testing is the hypothesis that aromatase inhibitors may be more beneficial than tamoxifen for HER2-positive, hormone-receptor-positive breast cancer patients. Overall, few trials directly investigate the key questions of this systematic review.

Going forward, cancer therapy trial protocols should incorporate elements to facilitate robust analyses of the use of HER2 status and other biomarkers for managing treatment. Given the human and financial cost of cancer therapy trials, the limited resources available, and the long duration of followup needed to assess outcomes, particularly for early stage or slowly growing cancers, it is imperative that tumor tissue blocks be collected, optimally fixed, saved, and made available for correlative tumor marker studies from all randomized patients. Agreement to share blocks with investigators should be made a condition for institutions seeking to participate in cooperative group trials.