# Acknowledgments

The research team would like to acknowledge the efforts of Maxine A. Gere, M.S., for general project management and editorial assistance; Elizabeth De La Garza and Joyce Gonzalez for administrative support; Ariel Katz, M.D., M.P.H., for study selection and data abstraction; Thomas Ratko, Ph.D., for fact-checking; and Gurvaneet Randhawa, M.D., M.P.H., for advice as our Task Order Officer.