# Introduction

The human epidermal growth factor (EGF) receptor-2 (HER2; also referred to as HER2/neu and as ERBB2) gene, located at position 17q12 on chromosome 17, is amplified (i.e., gene copy number greater than 2) and/or the HER2 protein is overexpressed (i.e., cell membrane has excess of HER2 protein molecules compared to normal cells) in approximately 18 to 20 percent of breast cancer cases (Owens, Horten, and Da Silva, 2004; Yaziji, Goldstein, Barry, et al., 2004; Wolff, Hammond, Schwartz, et al., 2007a; Slamon, Clark, Wong, et al., 1987; Hanna, O'Malley, Barnes, et al., 2007). Amplification and/or overexpression of HER2 have been associated with increased tumor aggressiveness and poor prognosis. The HER2 gene is one of four (HER1 through HER4) in the EGF receptor gene family; each codes for a membrane-spanning protein that can form homodimers and heterodimers and functions in signal transduction. All but HER2 bind (EGF or another) ligand outside the cell, and all but HER3 have enzymatic activity that phosphorylates tyrosine residues in proteins (i.e., tyrosine kinase activity) and that is activated by ligand binding. Ligand-activated tyrosine kinase initially phosphorylates tyrosine residues of the receptor's intracellular domain, and subsequently can phosphorylate tyrosine residues of other intracellular proteins. HER2 also is overexpressed in varying proportions of other epithelial malignancies such as ovarian, thyroid, lung, salivary gland/head and neck, stomach, colon and prostate cancers (Baselga and Mendelsohn 1994; Blank, Chang, and Muggia, 2005; Gross, Jos, and Agus, 2004). Table 1 provides a listing of the estimated new cases and deaths in the U.S. for these cancers in 2008.

Table 1 Estimated new cases and deaths in the U.S. in 2007 for epidermal cancers (of which varying proportions overexpress HER2) (Jemal, Siegel, Ward, et al., 2008)

Cancer Type | Estimated New Cases | Estimated Deaths
Breast cancer (female) | 182,460 | 40,480
Ovarian cancer | 21,650 | 15,520
Thyroid cancer | 37,340 | 1,590
Lung cancer | 215,020 | 161,840
Head and neck
• oral cavity/pharynx | 35,310 | 7,590
• larynx | 12,250 | 3,670
Stomach | 21,500 | 10,880
Colon | 108,070 | 49,960
Prostate | 186,320 | 28,860

## Implications of Accurately Determining HER2 Status

Laboratory assays for the HER2 gene and protein in tumor tissue are used to determine the HER2 status of patients with breast cancer (positive if either HER2 gene amplification or HER protein overexpression is present; negative if neither is present). As outlined in guideline recommendations for HER2 testing in breast cancer from the American Society of Clinical Oncology/College of American Pathologists (ASCO/CAP; Wolff, Hammond, Schwartz, et al., 2007a), and in a report from a task force of the National Comprehensive Cancer Network (NCCN; Carlson, Moench, Hammond, et al., 2006), information regarding a patient's HER2 status can contribute to treatment and other patient management decisions in several ways. HER2 overexpression has been associated with clinical outcomes in patients with breast cancer (Press, Pike, Chazin, et al., 1993; Press, Bernstein, Thomas, et al., 1997; Yamauchi, Stearns, Hayes, 2001). Because HER2 positivity is associated with a worse prognosis in patients with newly diagnosed breast cancer who do not receive systemic adjuvant chemotherapy, HER2 status may be incorporated along with other prognostic factors into decision making regarding such therapy (Wolff, Hammond, Schwartz, et al., 2007a; Carlson Moench, Hammond, et al., 2006).

HER2 positivity also appears to be associated with relative, but not absolute, resistance to certain endocrine therapies (e.g., tamoxifen; less so for aromatase inhibitors) and lower benefit from nonanthracycline, nontaxane-containing chemotherapy regimens (Konecny, Pauletti, Pegram, et al., 2003; Ellis, Coop, Singh, et al., 2001; Menard, Valagussa, Pilotti, et al., 2001). HER2 status is also used to determine whether a patient is eligible to receive biologic therapy specifically targeted to HER2 activity, e.g., trastuzumab (Herceptin®, Genentech, San Francisco, CA) or lapatinib (Tykerb®, GlaxoSmithKline, Research Triangle Park, NC).

Additionally, therapies have been developed that specifically target the HER2 protein (Dinh, de Azambuja, Piccart-Gebhart, et al., 2007; Pal and Pegram, 2007; Viani, Afonso, Stefano, et al., 2007; Lin and Rugo, 2007). Evidence from multiple randomized trials demonstrates that trastuzumab, a therapeutic monoclonal antibody that targets HER2, decreases the risk of recurrence and mortality when added to adjuvant chemotherapy regimens for resected HER2-positive breast cancer. A recent meta-analysis (five trials; pooled N=9,117) reported an odds ratio (OR) for mortality with versus without trastuzumab of 0.52 (95 percent CI: 0.44–0.62; p<0.00001), while OR for recurrence was 0.53 (95 percent CI: 0.46–0.60; p<.00001) (Viani, Alfonso, Stefano et al. 2007). In patients with metastatic HER2-positive breast cancer, trastuzumab alone or with chemotherapy increases time to disease progression and improves survival. Thus, there is increased emphasis on accurately determining the HER2 status of patients with newly diagnosed or recurrent breast cancer.

There are several assays available to measure or detect HER2 in tissue specimens: immunohistochemistry (IHC) assays measure overexpressed protein coded for by the HER2 gene, and in-situ hybridization techniques that rely on fluorescence (FISH), chromogenic (CISH), or silver-enhanced (SISH) assays, measure gene amplification (Table 2). Additionally, these and other methods (e.g., mRNA assays) can detect or measure HER2 in circulating tumor cells (Meng, Tripathy, Shete, et al., 2004; Apostolaki, Perraki, Pallis, et al., 2007). There is also a serum-based enzyme-linked immunosorbent assay (ELISA; Immuno 1®/ADVIA Centaur®, Bayer) that measures circulating levels of extracellular domain of HER2 (Carlson, Moench, Hammond, et al., 2006; Harris, Fritsche, Mennel, et al., 2007); however, the tissue-based assays are most commonly used to establish a patient's tumor HER2 status.

Table 2 HER2 assays used in tissue specimens and serum: clinical trials, clinical practice, and under development (adapted with permission from the American Society of Clinical Oncology; Wolff, Hammond, Schwartz, et al., 2007a and including information from Carlson, Moench, Hammond, et al., 2006)

A. IHC Assays: measure HER2 protein overexpression in tissue
Assay | Mfr | Methodology | Scoring Criteria | FDA Status
Clinical Trials Assay | Developed by independent laboratory | CB11 and 4D5 MAb | 0 and 1+ negative, 2+ weakly positive, 3+ strongly positive | Research assay used in trials of trastuzumab in metastatic breast cancer
HercepTest™ | DAKO* | A0485 polyclonal antibody | Weakly positive (2+): weak to moderate complete membrane staining in >10% of tumor cells; strongly positive (3+): strong complete membrane staining in >10% of tumor cells* | U.S. Food and Drug Administration (FDA) approved as an aid in the assessment of patients for whom Herceptin™ (trastuzumab) treatment is being considered
PATHWAY™ | Ventana† | CB11 MAb | Positive (2+): weak complete staining of the membrane, >10% of cancer cells; positive (3+): intense complete staining of the membrane, >10% of cancer cells† | FDA approved as an aid in the assessment of patients for whom Herceptin™ (trastuzumab) treatment is being considered
B. In-Situ Hybridization (ISH) Assays: measure HER2 gene amplification in tissue
PathVysion® HER2 DNA Probe Kit (FISH) | Abbott‡ | Hybridization of fluorescent DNA probes to HER2 gene (orange) and chromosome 17 centromere (green) | HER2 amplification: HER2/CEP17 ratio ≥2 on average for 60 cells; results at or near the cut off point (1.8–2.2) should be interpreted with caution (Persons, Tubbs, Cooley, et al., 2006; Dal Lago, Durbecq, Desmedt, et al., 2006) | FDA approved as an aid in the assessment of patients for whom Herceptin™ (trastuzumab) treatment is being considered
INFORM HER2/neu Probe (FISH) | Ventana§ | Hybridization of biotin-labeled DNA probe to HER2 gene and fluorescently labeled avidin | HER2 amplification: average of >6 HER2 gene copies/nucleus; an average of >4.0 <6.0 gene copies/nucleus for 60 cells described as equivocal in one publication (Dal Lago, Durbecq, Desmedt, et al., 2006; Vera-Roman and Rubio-Martinez, 2004) | FDA approved as an adjunct to existing clinical and pathologic information currently used as prognostic indicators in the risk stratification of breast cancer in patients with a primary, invasive, localized, node-negative tumor
HER2 FISH pharmDx™ Kit | Dako▿ | Hybridization of fluorescent DNA probes to HER2 gene (red) and PNA probes to chromosome 17 centromere (CEN-17; green) | Count 20 nuclei per tissue specimen, when possible from distinct tumor areas. Specimens with a HER2/CEN-17 ratio ≥2 should be considered HER2 gene amplified (Kallioniemi, Kallioniemi, Kurisu, et al., 1992; Ellis, Dowsett, Bartlett, et al., 2000; Hanna, 2001; Tsuda, Akiyama, Terasaki, et al., 2001). Results at or near the cut-off (1.8–2.2) should be interpreted with caution. If the ratio is borderline (1.8–2.2), count an additional 20 nuclei and recalculate the ratio for the 40 nuclei | FDA approved as an adjunct to clinicopathologic information currently used for estimating prognosis in stage II, node-positive breast cancer patients and as an aid in assessment of patients being considered for Herceptin™ (trastuzumab) treatment
SPoT-Light (CISH) | Invitrogen/Zymed¶ | Hybridization of digoxigenin-labeled DNA probe to HER2 gene; detection via mouse antidigoxigenin antibody followed by antimouse-peroxidase | High HER2 amplification defined as >10 dots, or large clusters, (low if >5 dots to 10 dots, or small clusters) or mixture of multiple dots and large clusters of the HER2 gene present per nucleus in >50% tumor cells (Hanna and Kwok, 2006) | DNA probe kit not available in the U.S.
EnzMet GenePro (SISH) | Ventana | Hybridization of dinitrophenol-labeled DNA probe to HER2 gene; detection via peroxidase-labeled multimer followed by enzyme metallography | Amplification defined as six or more dots, or large clusters of dots, in 30% or more of invasive tumor cells (Downs-Kelly, Pettay, Hicks, et al., 2005) | DNA probe kit not available in the U.S.
C. HER2 Extracellular Domain (ECD) Assays: detect HER2 ECD in serum
Immuno 1®/ADVIA Centaur® | Bayer | Enzyme immunoassay (EIA); primary MAbs NB-3 and TA-1 (one is labeled with fluorescein and the other is either linked to an enzyme or a chemiluminogenic molecule) specific for the ECD of HER2 added to sera; detection via binding of immunocomplex to antifluorescein antibodies in the solid phase, followed by addition of substrate in case of Immuno 1 assay | Elevated ECD concentrations often defined as >15 ng/mL (Payne, Allard, Anderson-Mauser, et al., 2000; Esteva, Cheli, Fritsche, et al., 2005) | FDA approval for followup and monitoring patients with metastatic breast cancer only

CISH: chromogenic in situ hybridization; ECD: extracellular domain; IHC: immunohistochemistry; FISH: fluorescent in situ hybridization; MAb: monoclonal antibody; Mfr: manufacturer; SISH: silver enhanced in situ hybridization;

* http://www.dakousa.com/prod_downloadpackageinsert.pdf?objectid_105073003

† http://www.ventanamed.com/products/files/ScoringGuide.pdf

▿ http://www.dakousa.com/prod_downloadpackageinsert.pdf?objectid=112853001

‡ http://www.vysis.com/PathVysionHER2DNAProbeKit_35793.asp

§ http://www.ventanamed.com/catalog/search_detail.html?id_402&categories_id_4

¶ https://catalog.invitrogen.com/index.cfm?fuseaction_viewCatalog.viewProductDetails&productDescription_10,952&CMP_LEC-GCMSSEARCH&HQS_HER2

## Key Questions for this Systematic Review

This systematic review will address five key questions regarding HER2 testing to manage patients with breast cancer or other solid tumors:

1 What is the evidence on concordance and discrepancy rates for methods (e.g., FISH, IHC, etc.) used to analyze HER2 status in breast tumor tissue?
2 For patients who are not unequivocally HER2 positive, what is the evidence on outcomes of treatment targeting the HER2 molecule (trastuzumab, etc.), or on differences in outcomes of a common chemotherapy or hormonal therapy regimen with versus without additional treatment targeting the HER2 molecule, in:
  a) Breast cancer patients characterized by discrepant HER2 results from different tissue assay methods performed adequately; and
  b) For those with HER2-negative breast cancer?
3 For breast cancer patients, what is the evidence on clinical benefits and harms of using HER2 assay results to guide selection of:
  a) Chemotherapy regimen; or
  b) Hormonal therapy?
4 What is the evidence that monitoring serum or plasma concentrations of HER2 extracellular domain in patients with HER2-positive breast cancer predicts response to therapy, or detects tumor progression or recurrence, and if so, what is the evidence that decisions based on serum or plasma HER2 assay results improve patient management and outcomes?
5 In patients with ovarian, lung, prostate, or head and neck cancers, what is the evidence that:
  a) Testing tumor tissue for HER2; or
  b) Monitoring serum or plasma concentrations of HER2;

either predicts response to therapy, or detects tumor progression or recurrence; and if so, what is the evidence that decisions based on HER2 assay results improve patient management and outcomes?

The first Key Question will be dealt with via a narrative review of the recent ASCO/CAP guidelines and evidence published subsequently.