# Appendix D. Technical Expert Panel (TEP) and Reviewers

## Technical Expert Panel (TEP)

- Robert Christenson, Ph.D.
- Director, Clinical Chemistry Laboratories
- Professor Pathology
- Medical & Research Technology
- University of Maryland Medical Center
- Baltimore, MD

- Daniel Hayes, M.D.
- Clinical Director, Breast Oncology Program
- University of Michigan Comprehensive Cancer Center
- Ann Arbor, MI

- Herbert A. Fritsche, Jr., Ph.D.
- Chief, Clinical Chemistry Section
- Department of Pathology and Laboratory Medicine
- The University of Texas
- M.D. Anderson Cancer Center
- Houston, TX

- Mark G. Kris, M.D.
- Chief, Thoracic Oncology Service
- Division of Solid Tumor Oncology
- Memorial Sloan-Kettering Cancer Center
- New York, NY

- Maurie Markman, M.D.
- Vice President, Clinical Research
- The University of Texas
- M.D. Anderson Cancer Center
- Houston, TX

- Evan R. Myers, M.D., M.P.H.
- Professor and Chief
- Division of Clinical and Epidemiological Research
- Department of Obstetrics and Gynecology
- Duke University Medical Center
- Durham, NC

- Frances P. O'Malley, M.B., F.R.C.P.C.
- Professor, Surgical Pathology
- Dept. of Pathology and Lab Medicine
- University of Toronto
- Toronto, ON

- Gurvaneet Randhawa MD, MPH
- Center for Outcomes and Evidence (COE)
- Agency for Healthcare Research and Quality
- Rockville, MD

- Alan Wu, Ph.D.
- Director, Clinical Chemistry and Toxicology
- University of California at San Francisco
- San Francisco, CA

- Vincent Stine, PhD
- Director, Government Affairs
- American Association for Clinical Chemistry
- Washington, DC

- Antonio C. Wolff, M.D., F.A.C.P.
- Johns Hopkins University
- Sidney Kimmel Cancer Center
- Baltimore, MD

## Peer Reviewers

- Søren Buur, Ph.D., M.B.A.
- Senior Global Product Manager pharmDx
- Product Marketing
- Dako Denmark A/S
- Denmark

- Robert W. Carlson, M.D.
- Professor of Medicine
- Division of Oncology
- Stanford Cancer Center
- Stanford, CA

- Walter Carney, PhD
- Oncogene Science/Bayer HealthCare LLC
- Siemens Medical Solutions Diagnostics
- Oncogene Science Biomarker Group
- Cambridge, MA

- Kathy Helzlsouer, M.D., M.H.S.
- Director
- Prevention and Research Center
- The Weinberg Center for Women's Health and Medicine
- Mercy Hospital
- Baltimore, MD

- M. Carolina Hinestrosa, M.A., M.P.H.
- Executive Vice President for Programs and Planning
- National Breast Cancer Coalition Fund
- Washington, DC

- Len Lichtenfeld, M.D., M.A.C.P.
- Deputy Chief Medical Officer
- American Cancer Society
- Atlanta, GA

- Susan J. Moench, Ph.D, P.A-C.
- National Comprehensive Cancer Network
- Jenkintown, PA

- Soonmyung Paik, MD
- Director, Division of Pathology
- NSABP (National Surgical Adjuvant Breast and Bowel Project)
- NSABP Operations Center
- Pittsburgh, PA

- William Sweet
- Business Area Manager
- Invitrogen Corporation
- Eugene, OR

- Jo Anne Zujewski, MD
- Senior Investigator
- National Cancer Institute
- Rockville, MD