# Appendix C. Evidence Data Abstraction Tables

Question 2: HER2-targeted Therapy for HER2 Discrepant/Negative Patients

Data Abstraction Table II-A. Design, Enrollment and Treatment.

Data Abstraction Table II-B. Patient Characteristics.

Data Abstraction Table II-C. HER2 Measurement Methods.

Data Abstraction Table II-D. Outcome Assessment.

Data Abstraction Table II-E. Time to Event Outcomes.

Data Abstraction Table II-F. Time to Event Outcome Regression Modeling.

Data Abstraction Table II-G. Tumor Response and Quality of Life.

Data Abstraction Table II-H. Response Regression Modeling.

Data Abstraction Table II-I. Adverse Events.

Question 3a: Tissue HER2 Results to Guide Selection of Chemotherapy Regimen

Data Abstraction Table IIIa-A. Design, Enrollment and Treatment.

Data Abstraction Table IIIa-B. Patient Characteristics.

Data Abstraction Table IIIa-C. HER2 Measurement Methods.

Data Abstraction Table IIIa-D. Outcome Assessment.

Data Abstraction Table IIIa-E. Time to Event Outcomes.

Data Abstraction Table IIIa-F. Time to Event Outcome Regression Modeling.

Data Abstraction Table IIIa-G. Tumor Response and Quality of Life.

Data Abstraction Table IIIa-H. Response Regression Modeling.

Data Abstraction Table IIIa-I. Adverse Events.

Data Abstraction Table IIIa-J. Study Quality Ratings.

Question 3b: Tissue HER2 Results to Guide Selection of Hormonal Therapy

Data Abstraction Table IIIb-A. Design, Enrollment and Treatment.

Data Abstraction Table IIIb-B. Patient Characteristics.

Data Abstraction Table IIIb-C. HER2 Measurement Methods.

Data Abstraction Table IIIb-D. Outcome Assessment.

Data Abstraction Table IIIb-E. Time to Event Outcomes.

Data Abstraction Table IIIb-F. Time to Event Outcome Regression Modeling.

Data Abstraction Table IIIb-G. Tumor Response and Quality of Life.

Data Abstraction Table IIIb-H. Response Regression Modeling.

Question 3: Tissue HER2 Results to Guide Treatment Regimen Selection

Data Abstraction Table IIIb-I. Adverse Events.

Data Abstraction Table IIIb-J. Randomized Trial Study Quality Ratings.

Data Abstraction Table IIIb-K. Case Series/Single Arm Trial Study Quality Ratings.

Question 4: Serum HER2 Results to Guide Treatment Regimen Selection

Data Abstraction Table IV-A. Design, Enrollment and Treatment.

Data Abstraction Table IV-B. Patient Characteristics.

Data Abstraction Table IV-C. HER2 Measurement Methods.

Data Abstraction Table IV-D. Outcome Assessment.

Data Abstraction Table IV-E. Time to Event Outcomes.

Data Abstraction Table IV-F. Time to Event Outcome Regression Modeling.

Data Abstraction Table IV-G. Tumor Response and Quality of Life.

Data Abstraction Table IV-H. Response Regression Modeling.

Data Abstraction Table IV-I. Adverse Events.

Data Abstraction Table IV-J. Randomized Trial Study Quality Ratings.

Data Abstraction Table IV-K. Case Series/Single Arm Trial Study Quality Ratings.

Question 5: HER2 Results to Guide Treatment Regimen Selection

Data Abstraction Table V-A. Lung Cancer: Design, Enrollment and Treatment.

Data Abstraction Table V-B. Lung Cancer: Patient Characteristics.

Data Abstraction Table V-C. Lung Cancer: HER2 Measurement Methods.

Data Abstraction Table V-D. Lung Cancer: Outcome Assessment.

Data Abstraction Table V-E. Time to Event Outcomes.

Data Abstraction Table V-F. Lung Cancer: Time to Event Outcome Regression Modeling.

Data Abstraction Table V-G. Lung Cancer: Tumor Response and Quality of Life.

Data Abstraction Table V. Lung Cancer: Adverse Events.

Data Abstraction Table V-J. Lung Cancer: Randomized Trial Study Quality Ratings.

Data Abstraction Table V-K. Lung Cancer: Case Series/Single Arm Trial Study Quality Ratings.

Data Abstraction Table V-L. Ovarian Cancer. Design, Enrollment and Treatment.

Data Abstraction Table V-M. Ovarian Cancer. Patient Characteristics.

Data Abstraction Table V-N. Ovarian Cancer. HER2 Measurement Methods.

Data Abstraction Table V-O. Ovarian Cancer. Outcome Assessment.

Data Abstraction Table V-p. Ovarian Cancer. Time to Event Outcomes.

Data Abstraction Table V-Q. Ovarian Cancer. Time to Event Outcome Regression Modeling.

Data Abstraction Table V-R. Ovarian Cancer. Tumor Response and Quality of Life.

Data Abstraction Table V-S. Ovarian Cancer. : Response Regression Modeling.

Data Abstraction Table V-T. Ovarian Cancer. Adverse Events.

Data Abstraction Table V-U. Ovarian Cancer. Randomized Trial Study Quality Ratings.

Data Abstraction Table V-V. Ovarian Cancer. Case Series/Single Arm Trial Study Quality Ratings.

Data Abstraction Table V-W. Prostate Cancer. Design, Enrollment and Treatment.

Data Abstraction Table V-X. Prostate Cancer. Patient Characteristics.

Data Abstraction Table V-Y. Prostate Cancer. HER2 Measurement Methods.

Data Abstraction Table V-Z. Prostate Cancer. Outcome Assessment.

Data Abstraction Table V-AA. Prostate Cancer. Time to Event Outcomes.

Data Abstraction Table V-BB. Prostate Cancer. Time to Event Outcome Regression Modeling.

Data Abstraction Table V-CC. Prostate Cancer. Tumor Response and Quality of Life.

Data Abstraction Table V-DD. Prostate Cancer. Response Regression Modeling.

Data Abstraction Table V-EE. Prostate Cancer. Adverse Events.

Data Abstraction Table V-FF. Prostate Cancer. Randomized Trial Study Quality Ratings.

Data Abstraction Table V-GG. Prostate Cancer. Case Series/Single Arm Trial Study Quality Ratings.

Data Abstraction Table V-HH. Head and Neck Cancer. Design, Enrollment and Treatment.

Data Abstraction Table V-II. Head and Neck Cancer. Patient Characteristics.

Data Abstraction Table V-JJ. Head and Neck Cancer. HER2 Measurement Methods.

Data Abstraction Table V-KK. Head and Neck Cancer. Outcome Assessment.

Data Abstraction Table V-LL. Head and Neck Cancer. Time to Event Outcomes.

Data Abstraction Table V-MM. Head and Neck Cancer. Time to Event Outcome Regression Modeling.

Data Abstraction Table V-NN. Head and Neck Cancer. Tumor Response and Quality of Life.

Data Abstraction Table V-OO. Head and Neck Cancer. Response Regression Modeling.

Data Abstraction Table V-PP. Head and Neck Cancer. Adverse Events.

Data Abstraction Table V-QQ. Head and Neck Cancer. Randomized Trial Study Quality Ratings.

Data Abstraction Table V-RR. Head and Neck Cancer. Case Series/Single Arm Trial Study Quality Ratings.

Table Abstraction Table II-A Design, Enrollment and Treatment

Study | Design | Therapeutic Setting | n, Enrolled (n per group) | n, Evaluated | n, withdrawn or lost to F/U | Treatment Regimen (Agents)
HER2 Discrepant
Paik et al. 2007; Kim et al, in preparation; Romond et al. 2005 | RCT NSABP-B31 | adjuvant therapy | 2043 (1024, 1019) | 1829 w tumor blocks; 1795 w baseline and F/U data | 248 | AC→ (P ± trastuzumab)
Perez et al. 2007; Perez et al. 2006; Romond et al. 2005 | RCT NCCTG N9831 | adjuvant therapy | 1842 | 1779 (895, 884) | 63 | AC→ (P ± trastuzumab)
HER2 Negative
Seidman et al. 2004 | RCT CALGB 9840 | inoperable or metastatic disease, stratified by 1^st^ or 2^nd^ line therapy | 735 | 228 (HER2-) (113, 115) | 0 (507 HER2+ or UNK given TRZ) | 4 arm trial: P (weekly vs. q3w) stratified by HER2 status; HER2- randomized to ± TRZ, all HER2+ given TRZ
Kaufman et al. 2007 | RCT CALGB 150002 | metastatic, 1^st^ or 2^nd^ line; companion study on CALGB 9840 pts | 585 | 303 (samples available for central testing) | 282 | 4 arm trial: P (weekly vs. q3w) stratified by HER2 status; HER2- randomized to ± TRZ, all HER2+ given TRZ

Table II-B Patient Characteristics

Study | Age/Menopausal Status | | | Race (%) | | Disease Stage | | | Disease Stage (%) | | | Performance Status | | | Hormone Receptor Status (%)
HER2 Discrepant
NSABP B-31 Paik et al. 2007; Kim et al, in preparation; Romond et al. 2005; Tan-Chiu et al. 2005 | | -TRZ | +TRZ | of n=1664 evaluable in Tan-Chiu et al. | | | -TRZ | +TRZ | | -TRZ1 | +TRZ | Scale | Grp1 | Grp2 | | -TRZ | +TRZ
NSABP B-31 Paik et al. 2007; Kim et al, in preparation; Romond et al. 2005; Tan-Chiu et al. 2005 | ≤39 | 16.7% | 16.2% | B | 8 | I | NR | | ≤2 cm | 40.7 | 37.3 | not reported (likely not relevant in adjuvant setting) | | | ER+ | 52.8 | 51.9
NSABP B-31 Paik et al. 2007; Kim et al, in preparation; Romond et al. 2005; Tan-Chiu et al. 2005 | 40-9 | 34.9% | 35.4% | W | 84 | IIa | NR | | 2–4 cm | 42.7 | 44.7 | | | | PR+ | 41.4 | 39.0
NSABP B-31 Paik et al. 2007; Kim et al, in preparation; Romond et al. 2005; Tan-Chiu et al. 2005 | 50-9 | 33.7% | 32.4% | H | | IIb | NR | | ≥4.1 cm | 14.4 | 16.7
NSABP B-31 Paik et al. 2007; Kim et al, in preparation; Romond et al. 2005; Tan-Chiu et al. 2005 | ≥60 | 14.7% | 16.0% | A | | IIIa | NR | | unknown | 2.2 | 1.4
NSABP B-31 Paik et al. 2007; Kim et al, in preparation; Romond et al. 2005; Tan-Chiu et al. 2005 | pre | NR | | O | 8 | IIIb | NR | | pN0 | 0 | 0
NSABP B-31 Paik et al. 2007; Kim et al, in preparation; Romond et al. 2005; Tan-Chiu et al. 2005 | intra | NR | | | | IV | 0 | | pN1 | 56.7 | 57.4
NSABP B-31 Paik et al. 2007; Kim et al, in preparation; Romond et al. 2005; Tan-Chiu et al. 2005 | post | NR | | | | | | | pN2 | 29.0 | 29.1
| | | | | | | | pN3 | 14.3 | 13.5
NCCTG N9831 Perez et al. 2007; Perez et al. 2006; Romond et al. 2005 | | -TRZ | +TRZ | | | | -TRZ | +TRZ | | -TRZ1 | +TRZ | Scale | Grp1 | Grp2 | | -TRZ | +TRZ
NCCTG N9831 Perez et al. 2007; Perez et al. 2006; Romond et al. 2005 | ≤39 | 17.1% | 16.0% | B | not reported | I | NR | | ≤2 cm | 40.0 | 38.0 | not reported (likely not relevant in adjuvant setting) | | | ER+ | 52.8 | 51.2
NCCTG N9831 Perez et al. 2007; Perez et al. 2006; Romond et al. 2005 | 40-9 | 34.0% | 33.7% | W | not reported | IIa | NR | | 2–4 cm | 46.1 | 47.3 | | | | PR+ | 41.3 | 39.4
NCCTG N9831 Perez et al. 2007; Perez et al. 2006; Romond et al. 2005 | 50-9 | 33.7% | 32.3% | H | not reported | IIb | NR | | ≥4.1 cm | 12.6 | 14.2
NCCTG N9831 Perez et al. 2007; Perez et al. 2006; Romond et al. 2005 | ≥60 | 15.2% | 18.1% | A | not reported | IIIa | NR | | unknown | 1.2 | 0.5
NCCTG N9831 Perez et al. 2007; Perez et al. 2006; Romond et al. 2005 | pre | NR | | O | IIIb | NR | | pN0 | 12.6 | 11.0
NCCTG N9831 Perez et al. 2007; Perez et al. 2006; Romond et al. 2005 | intra | NR | | | | IV | 0 | | pN1 | 47.8 | 49.9
NCCTG N9831 Perez et al. 2007; Perez et al. 2006; Romond et al. 2005 | post | NR | | | | | | | pN2 | 25.2 | 25.4
| | | | | | | | pN3 | 13.9 | 13.7
HER2 Negative
CALGB 9840 Seidman et al. 2004 (no separate data for HER2- group randomized to ±TRZ) | mn | | | B | not reported | IIa | | | Mn T | | | Scale not stated | 92% PS 0–1 | | ER+ | 51%
CALGB 9840 Seidman et al. 2004 (no separate data for HER2- group randomized to ±TRZ) | md | | | W | not reported | IIb | | | T1 | | | | | | PR+ | not reported
CALGB 9840 Seidman et al. 2004 (no separate data for HER2- group randomized to ±TRZ) | rng | | | H | not reported | IIIa | | | T2
CALGB 9840 Seidman et al. 2004 (no separate data for HER2- group randomized to ±TRZ) | sd | | | A | not reported | IIIb | | | T3 | not reported
CALGB 9840 Seidman et al. 2004 (no separate data for HER2- group randomized to ±TRZ) | pre | 19% | | O | IV | 100% | | T4
CALGB 9840 Seidman et al. 2004 (no separate data for HER2- group randomized to ±TRZ) | intra | | | | | | | | N0
CALGB 9840 Seidman et al. 2004 (no separate data for HER2- group randomized to ±TRZ) | post | | | | | | | | N1
| | | | | | | | N2
CALGB 150002 Kaufman et al. 2007 | not reported | | | not reported | | IIa | | | not reported | | | not reported | | | not reported
CALGB 150002 Kaufman et al. 2007 | | | | | | IIb
CALGB 150002 Kaufman et al. 2007 | | | | | | IIIa
CALGB 150002 Kaufman et al. 2007 | | | | | | IIIb
| | | | | IV | 100%

Table II-C HER2 Measurement Methods

Study | Assays (Name) | | Criteria for Positivity | Test Results (%) | | Comments
HER2 Discrepant
Paik et al. 2007; Kim et al, in preparation; | FISH | PathVysion™ | FISH: | Pos | 1588 (88.5) | reports on discrepant and Her2- subsets by central lab results central IHC results missing due to assay failure for 8 patients (0.5% of total, n=1795)
Paik et al. 2007; Kim et al, in preparation; | IHC | HercepTest™ | scored as per FDA labeling | Equiv | 0 | reports on discrepant and Her2- subsets by central lab results central IHC results missing due to assay failure for 8 patients (0.5% of total, n=1795)
Paik et al. 2007; Kim et al, in preparation; | (performed by NSABP Division of Pathology Central Laboratory; all considered HER2+ by local laboratories) | | | Neg | 207 (11.5) | reports on discrepant and Her2- subsets by central lab results central IHC results missing due to assay failure for 8 patients (0.5% of total, n=1795)
Paik et al. 2007; Kim et al, in preparation; | | | IHC: | 3+ | 1488 (82.9) | reports on discrepant and Her2- subsets by central lab results central IHC results missing due to assay failure for 8 patients (0.5% of total, n=1795)
Paik et al. 2007; Kim et al, in preparation; | | | scored as per FDA labeling | 2+ | 146 (8.1) | reports on discrepant and Her2- subsets by central lab results central IHC results missing due to assay failure for 8 patients (0.5% of total, n=1795)
Paik et al. 2007; Kim et al, in preparation; | | | | 1+ | 119 (6.6) | reports on discrepant and Her2- subsets by central lab results central IHC results missing due to assay failure for 8 patients (0.5% of total, n=1795)
| | | 0 | 34 (1.9)
Perez et al. 2007; Perez et al. 2006; Romond et al. 2005 | FISH | PathVysion™ | FISH: | Pos | 1623 (91.2) | reports on discrepant and HER2- subsets by central lab results
Perez et al. 2007; Perez et al. 2006; Romond et al. 2005 | IHC | HercepTest™ | scored as per FDA labeling | Equiv | 0 | reports on discrepant and HER2- subsets by central lab results
Perez et al. 2007; Perez et al. 2006; Romond et al. 2005 | (performed by Mayo Medical Labs and a reference laboratory; all considered HER2+ by local laboratories) | | | Neg | 156 (8.8) | reports on discrepant and HER2- subsets by central lab results
Perez et al. 2007; Perez et al. 2006; Romond et al. 2005 | (data from Prez et al. 2007, slide 18) | | IHC: | 3+ | 1458 (82.0) | reports on discrepant and HER2- subsets by central lab results
| | scored as per FDA labeling | <3+ | 321 (18.0)
HER2 Negative
CALGB 9840 Seidman et al. 2004 | IHC, with FISH if 2+; reported reported based on local assessment only | | IHC 3+ or 2+/FISH+ | Pos | 507 (69.0)
CALGB 9840 Seidman et al. 2004 | | | | Equiv
| | | Neg | 228 (31.0)
CALGB 150002 Kaufman et al. 2007 | FISH | PathVysion™, with CEP17 to detect polysomy | polysomy = >2.2 copies of centromere 17 despite FISH ratio <2.0 | n=265, central FISH+ or no polysomy
CALGB 150002 Kaufman et al. 2007 | IHC | HercepTest™ | | n=38, polysomy and central FISH- (19% of central FISH-)
| | | (n=3, IHC 3+; n=35, IHC<3+)

Table II-D Outcome Assessment

Study | Primary Outcomes | Secondary Outcomes | Response Criteria | Independent Response Assessor | F/U Frequency/Duration
HER2 Discrepant
Paik et al. 2007; Kim et al, in preparation; Romond et al. 2005 | disease-free survival | overall survival; time to distant recurrence; breast cancer specific survival; | not relevant (adjuvant therapy) | not relevant | baseline, 3 months, then every 6 months to 5 years, and yearly thereafter (for cardiac toxicity); median F/U duration: 2.4 years
Perez et al. 2007; Perez et al. 2006; Romond et al. 2005 | disease-free survival | overall survival; time to distant recurrence; breast cancer specific survival (but none reported for HER2- or discrepant subgroups) | not relevant (adjuvant therapy) | not relevant | baseline, 3 months, then every 6 months to 5 years, and yearly thereafter (for cardiac toxicity); median F/U duration: 1.5 years
HER2 Negative
CALGB 9840 Seidman et al. 2004 | tumor response rate | time to progression, overall survival | not reported | not reported | not reported
CALGB 150002 Kaufman et al. 2007 | tumor response rate | overall survival, time to progression | not reported | not reported | not reported

Table II-E Time to Event Outcomes

Study | Time to Event Outcomes
HER2 Discrepant, Adjuvant Therapy
Paik et al. 2007; Kim et al, in preparation; Romond et al. 2005 FISH+ IHC- (0, 1+, 2+) by central lab | Outcome | Grp | N | Med (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | Test | p | HR (95%CI) | Comments
Paik et al. 2007; Kim et al, in preparation; Romond et al. 2005 FISH+ IHC- (0, 1+, 2+) by central lab | OS | Tx
Paik et al. 2007; Kim et al, in preparation; Romond et al. 2005 FISH+ IHC- (0, 1+, 2+) by central lab | | Cx
Paik et al. 2007; Kim et al, in preparation; Romond et al. 2005 FISH+ IHC- (0, 1+, 2+) by central lab | RFI* | Tx | 56 | | | | | | | Cox prop hazards | 0.11 | 0.35 (0.10–1.28) | adjusted for ER and nodal status
Paik et al. 2007; Kim et al, in preparation; Romond et al. 2005 FISH+ IHC- (0, 1+, 2+) by central lab | | Cx | 69
Paik et al. 2007; Kim et al, in preparation; Romond et al. 2005 FISH+ IHC- (0, 1+, 2+) by central lab | PFS | Tx
Paik et al. 2007; Kim et al, in preparation; Romond et al. 2005 FISH+ IHC- (0, 1+, 2+) by central lab | | Cx
Paik et al. 2007; Kim et al, in preparation; Romond et al. 2005 FISH+ IHC- (0, 1+, 2+) by central lab | RFS | Tx
Paik et al. 2007; Kim et al, in preparation; Romond et al. 2005 FISH+ IHC- (0, 1+, 2+) by central lab | | Cx
Paik et al. 2007; Kim et al, in preparation; Romond et al. 2005 FISH+ IHC- (0, 1+, 2+) by central lab | DFS | Tx | 56 | | | | | | | Cox prop hazards | 0.064 | 0.30 (0.08–1.07) | adjusted for ER and nodal status
Paik et al. 2007; Kim et al, in preparation; Romond et al. 2005 FISH+ IHC- (0, 1+, 2+) by central lab | | Cx | 69
Paik et al. 2007; Kim et al, in preparation; Romond et al. 2005 FISH+ IHC- (0, 1+, 2+) by central lab | DSS | Tx
| Cx
Paik et al. 2007; Kim et al, in preparation; Romond et al. 2005 FISH- IHC 3+ by central lab | Outcome | Grp | N | Med (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | Test | p | HR (95%CI) | Comments
Paik et al. 2007; Kim et al, in preparation; Romond et al. 2005 FISH- IHC 3+ by central lab | OS | Tx
Paik et al. 2007; Kim et al, in preparation; Romond et al. 2005 FISH- IHC 3+ by central lab | | Cx
Paik et al. 2007; Kim et al, in preparation; Romond et al. 2005 FISH- IHC 3+ by central lab | RFI* | Tx | 10 | | | | | | | Cox prop hazards | 0.94 | 0.91 (0.08–10) | adjusted for ER and nodal status
Paik et al. 2007; Kim et al, in preparation; Romond et al. 2005 FISH- IHC 3+ by central lab | | Cx | 21
Paik et al. 2007; Kim et al, in preparation; Romond et al. 2005 FISH- IHC 3+ by central lab | PFS | Tx
Paik et al. 2007; Kim et al, in preparation; Romond et al. 2005 FISH- IHC 3+ by central lab | | Cx
Paik et al. 2007; Kim et al, in preparation; Romond et al. 2005 FISH- IHC 3+ by central lab | RFS | Tx
Paik et al. 2007; Kim et al, in preparation; Romond et al. 2005 FISH- IHC 3+ by central lab | | Cx
Paik et al. 2007; Kim et al, in preparation; Romond et al. 2005 FISH- IHC 3+ by central lab | DFS | Tx | 10 | | | | | | | Cox prop hazards | 0.94 | 0.91 (0.08–10) | adjusted for ER and nodal status
Paik et al. 2007; Kim et al, in preparation; Romond et al. 2005 FISH- IHC 3+ by central lab | | Cx | 21
Paik et al. 2007; Kim et al, in preparation; Romond et al. 2005 FISH- IHC 3+ by central lab | DSS | Tx
| Cx
Perez et al. 2007; Perez et al. 2006; Romond et al. 2005 | DFS | Grp | N | Med (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | Test | p | HR (95%CI) | Comments
Perez et al. 2007; Perez et al. 2006; Romond et al. 2005 | FISH+ | Tx | 123 | | | | | | | ??? | 0.97 | 0.98 (0.33–2.91) | pools IHC 2+ with 0, 1+
Perez et al. 2007; Perez et al. 2006; Romond et al. 2005 | IHC<3+ | Cx | 95
Perez et al. 2007; Perez et al. 2006; Romond et al. 2005 | FISH- | Tx | 23 | | | | | | ??? | 0.57 | 0.61 (0.11–3.29)
IHC3+ | Cx | 30
Paik et al. 2007; Kim et al, in preparation; Romond et al. 2005 FISH- IHC 1+, 2+ by central lab | Outcome | Grp | N | Med (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | Test | p | HR (95%CI) | Comments
Paik et al. 2007; Kim et al, in preparation; Romond et al. 2005 FISH- IHC 1+, 2+ by central lab | OS | Tx
Paik et al. 2007; Kim et al, in preparation; Romond et al. 2005 FISH- IHC 1+, 2+ by central lab | | Cx
Paik et al. 2007; Kim et al, in preparation; Romond et al. 2005 FISH- IHC 1+, 2+ by central lab | RFI* | Tx | 69 | | | | | | | Cox prop hazards | 0.041 | 0.31(0.10–0.95) | adjusted for ER and nodal status
Paik et al. 2007; Kim et al, in preparation; Romond et al. 2005 FISH- IHC 1+, 2+ by central lab | | Cx | 80
Paik et al. 2007; Kim et al, in preparation; Romond et al. 2005 FISH- IHC 1+, 2+ by central lab | PFS | Tx
Paik et al. 2007; Kim et al, in preparation; Romond et al. 2005 FISH- IHC 1+, 2+ by central lab | | Cx
Paik et al. 2007; Kim et al, in preparation; Romond et al. 2005 FISH- IHC 1+, 2+ by central lab | RFS | Tx
Paik et al. 2007; Kim et al, in preparation; Romond et al. 2005 FISH- IHC 1+, 2+ by central lab | | Cx
Paik et al. 2007; Kim et al, in preparation; Romond et al. 2005 FISH- IHC 1+, 2+ by central lab | DFS | Tx | 69 | | ~98% | ~95% | ~90% | ~90% | ~86% | Cox prop hazards | 0.02 | 0.30 (0.11–0.83) | adjusted for ER and nodal status
Paik et al. 2007; Kim et al, in preparation; Romond et al. 2005 FISH- IHC 1+, 2+ by central lab | | Cx | 80 | | ~90% | ~79% | ~75% | ~70% | ~62%
Paik et al. 2007; Kim et al, in preparation; Romond et al. 2005 FISH- IHC 1+, 2+ by central lab | DSS | Tx
| Cx
Paik et al. 2007; Kim et al, in preparation; Romond et al. 2005 FISH- IHC-(0, 1+, 2+) by central lab | Outcome | Grp | N | Med (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | Test | p | HR (95%CI) | Comments
Paik et al. 2007; Kim et al, in preparation; Romond et al. 2005 FISH- IHC-(0, 1+, 2+) by central lab | OS | Tx
Paik et al. 2007; Kim et al, in preparation; Romond et al. 2005 FISH- IHC-(0, 1+, 2+) by central lab | | Cx
Paik et al. 2007; Kim et al, in preparation; Romond et al. 2005 FISH- IHC-(0, 1+, 2+) by central lab | RFI* | Tx | 82 | | | | | | | Cox prop hazards | 0.034 | 0.36 (0.14–0.92 | adjusted for ER and nodal status
Paik et al. 2007; Kim et al, in preparation; Romond et al. 2005 FISH- IHC-(0, 1+, 2+) by central lab | | Cx | 92
Paik et al. 2007; Kim et al, in preparation; Romond et al. 2005 FISH- IHC-(0, 1+, 2+) by central lab | PFS | Tx
Paik et al. 2007; Kim et al, in preparation; Romond et al. 2005 FISH- IHC-(0, 1+, 2+) by central lab | | Cx
Paik et al. 2007; Kim et al, in preparation; Romond et al. 2005 FISH- IHC-(0, 1+, 2+) by central lab | RFS | Tx
Paik et al. 2007; Kim et al, in preparation; Romond et al. 2005 FISH- IHC-(0, 1+, 2+) by central lab | | Cx
Paik et al. 2007; Kim et al, in preparation; Romond et al. 2005 FISH- IHC-(0, 1+, 2+) by central lab | DFS | Tx | 82 | | ~97% | ~90% | ~87% | ~87% | ~84% | Cox prop hazards | 0.014 | 0.34 (0.14–0.80) | adjusted for ER and nodal status
Paik et al. 2007; Kim et al, in preparation; Romond et al. 2005 FISH- IHC-(0, 1+, 2+) by central lab | | Cx | 92 | | ~92% | ~80% | ~76% | ~72% | ~65%
Paik et al. 2007; Kim et al, in preparation; Romond et al. 2005 FISH- IHC-(0, 1+, 2+) by central lab | DSS | Tx
| Cx
Perez et al. 2007; Perez et al. 2006; Romond et al. 2005 FISH- IHC- (0, 1+, 2+) by central lab | Outcome | Grp | N | Med (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | Test | p | HR (95%CI) | Comments
Perez et al. 2007; Perez et al. 2006; Romond et al. 2005 FISH- IHC- (0, 1+, 2+) by central lab | OS | Tx
Perez et al. 2007; Perez et al. 2006; Romond et al. 2005 FISH- IHC- (0, 1+, 2+) by central lab | | Cx
Perez et al. 2007; Perez et al. 2006; Romond et al. 2005 FISH- IHC- (0, 1+, 2+) by central lab | TTP | Tx
Perez et al. 2007; Perez et al. 2006; Romond et al. 2005 FISH- IHC- (0, 1+, 2+) by central lab | | Cx
Perez et al. 2007; Perez et al. 2006; Romond et al. 2005 FISH- IHC- (0, 1+, 2+) by central lab | PFS | Tx
Perez et al. 2007; Perez et al. 2006; Romond et al. 2005 FISH- IHC- (0, 1+, 2+) by central lab | | Cx
Perez et al. 2007; Perez et al. 2006; Romond et al. 2005 FISH- IHC- (0, 1+, 2+) by central lab | RFS | Tx
Perez et al. 2007; Perez et al. 2006; Romond et al. 2005 FISH- IHC- (0, 1+, 2+) by central lab | | Cx
Perez et al. 2007; Perez et al. 2006; Romond et al. 2005 FISH- IHC- (0, 1+, 2+) by central lab | DFS | Tx | 59 | | | | | | | ??? | 0.13 | 0.51 (0.21–1.2)
Perez et al. 2007; Perez et al. 2006; Romond et al. 2005 FISH- IHC- (0, 1+, 2+) by central lab | | Cx | 44
Perez et al. 2007; Perez et al. 2006; Romond et al. 2005 FISH- IHC- (0, 1+, 2+) by central lab | DSS | Tx
| Cx
HER2 Negative, Therapy for Metastasis
CALGB 9840 Seidman et al. 2004 IHC2+/FISH- or IHC 0, 1+ | Outcome | Grp | N | Med (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | Test | p | HR (95%CI) | Comments
CALGB 9840 Seidman et al. 2004 IHC2+/FISH- or IHC 0, 1+ | OS | Tx | 113 | 21.6 | ~75% | ~40% | ~25% | | | ??? | 0.67
CALGB 9840 Seidman et al. 2004 IHC2+/FISH- or IHC 0, 1+ | | Cx | 115 | 19.6 | ~70% | ~37% | ~22%
CALGB 9840 Seidman et al. 2004 IHC2+/FISH- or IHC 0, 1+ | TTP | Tx | 113 | 7.3 | ~30% | ~18% | ~10% | | | ??? | 0.088
CALGB 9840 Seidman et al. 2004 IHC2+/FISH- or IHC 0, 1+ | | Cx | 115 | 5.5 | ~25% | ~10% | ~10%
CALGB 9840 Seidman et al. 2004 IHC2+/FISH- or IHC 0, 1+ | PFS | Tx
CALGB 9840 Seidman et al. 2004 IHC2+/FISH- or IHC 0, 1+ | | Cx
CALGB 9840 Seidman et al. 2004 IHC2+/FISH- or IHC 0, 1+ | RFS | Tx
CALGB 9840 Seidman et al. 2004 IHC2+/FISH- or IHC 0, 1+ | | Cx
CALGB 9840 Seidman et al. 2004 IHC2+/FISH- or IHC 0, 1+ | DFS | Tx
CALGB 9840 Seidman et al. 2004 IHC2+/FISH- or IHC 0, 1+ | | Cx
CALGB 9840 Seidman et al. 2004 IHC2+/FISH- or IHC 0, 1+ | DSS | Tx
| Cx
CALGB 150002 Kaufman et al. 2007 central FISH- with polysomy 17 from CALGB 9840 | Outcome | Grp | N | Med (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | Test | p | HR (95%CI) | Comments
CALGB 150002 Kaufman et al. 2007 central FISH- with polysomy 17 from CALGB 9840 | OS | Tx | 19 | ~30 | ~90% | ~65% | ~30% | | | ??? | 0.538
CALGB 150002 Kaufman et al. 2007 central FISH- with polysomy 17 from CALGB 9840 | | Cx | 19 | ~23 | ~69% | ~48% | ~30%
CALGB 150002 Kaufman et al. 2007 central FISH- with polysomy 17 from CALGB 9840 | TTP | Tx | 19 | ~12 | ~50% | ~15% | 0 | | | | ??? | 0.888
CALGB 150002 Kaufman et al. 2007 central FISH- with polysomy 17 from CALGB 9840 | | Cx | 19 | ~6 | ~29% | ~23% | ~17%
CALGB 150002 Kaufman et al. 2007 central FISH- with polysomy 17 from CALGB 9840 | PFS | Tx
CALGB 150002 Kaufman et al. 2007 central FISH- with polysomy 17 from CALGB 9840 | | Cx
CALGB 150002 Kaufman et al. 2007 central FISH- with polysomy 17 from CALGB 9840 | RFS | Tx
CALGB 150002 Kaufman et al. 2007 central FISH- with polysomy 17 from CALGB 9840 | | Cx
CALGB 150002 Kaufman et al. 2007 central FISH- with polysomy 17 from CALGB 9840 | DFS | Tx
CALGB 150002 Kaufman et al. 2007 central FISH- with polysomy 17 from CALGB 9840 | | Cx
CALGB 150002 Kaufman et al. 2007 central FISH- with polysomy 17 from CALGB 9840 | DSS | Tx
| Cx

* RFI = recurrence-free interval

Table II-F Time to Event Outcome Regression Modeling

Study | Design/Outcome/Model | Candidate Predictors/Method for Identifying Candidates | Univariate Results, Variable (p value) | Selected Predictors/Methods for Selecting Predictors for Multivariate Model | Proportional Hazards Assumption Assessed?/Interactions Considered? | Multivariate Model Results, Variable (p value) | Discrimination/Validation Methods/Results | Calibration/Goodness of Fit
HER2 Discrepant
Paik et al. 2007; Kim et al, in preparation; Romond et al. 2005 | study used a Cox proportional hazards model to estimate HR and adjust for two covariates (estrogen receptor status and nodal status); however, Methods section of draft article provided insufficient detail and lacked table(s) on other candidate predictors, univariate results, etc.
Perez et al. 2007; Perez et al. 2006; Romond et al. 2005 | insufficient information provided in slides and abstract
HER2 Negative
Paik et al. 2007; Kim et al, in preparation; Romond et al. 2005 | study used a Cox proportional hazards model to estimate HR and adjust for two covariates (estrogen receptor status and nodal status); however, Methods section of draft article provided insufficient detail and lacked table(s) on other candidate predictors, univariate results, etc.
Perez et al. 2007; Perez et al. 2006; Romond et al. 2005 | insufficient information provided in slides and abstract
CALGB 9840 Seidman et al. 2004 | not reported
CALGB 150002 Kaufman et al. 2007 | not reported

Table II-G Tumor Response and Quality of Life

Study | Tumor Response | | | | | | | | | | Quality of Life
HER2 Discrepant (IHC 2+/FISH+)
Paik et al. 2007; Kim et al, in preparation; Romond et al. 2005 | Grp | N | CR | PR | SD | PD | NE | Test | p | Comments | Scale | Domain | F/U | Grp | n | mn±sd
| not reported | | | | | | | | | | not reported
Perez et al. 2007; Perez et al. 2006; Romond et al. 2005 | Grp | N | CR | PR | SD | PD | NE | Test | p | Comments | Scale | Domain | F/U | Grp | n | mn±sd
| not reported | | | | | | | | | | not reported
HER2 Negative
CALGB 9840 Seidman et al. 2004 | Grp | N | CR | PR | SD | PD | NE | Test | p | Comments | Scale | Domain | F/U | Grp | n | mn±sd
| +TRZ | 112 | 35% (CR+PR) | | | | | ??? | 0.34 | p=0.32 by multivariate logistic regression | not reported
| -TRZ | 111 | 29% (CR+PR)
CALGB 150002 Kaufman et al. 2007 central FISH- from CALGB 9840 | Grp | N | CR | PR | SD | PD | NE | Test | p | Comments | Scale | Domain | F/U | Grp | n | mn±sd
| +TRZ | 19 | 63% (CR+PR) | | | | | ??? | 0.048 | FISH-/polysomy+ | | | not reported
| - TRZ | 19 | 26% (CR+PR)
| +TRZ | 53 | 36% (CR+PR) | | | | | ??? | NS | FISH-/polysomy-
| - TRZ | 50 | 36% (CR+PR)

Table II-H Response Regression Modeling

Study | Design/Outcome/Model | Candidate Predictors/Method for Identifying Candidates | Univariate Results, Variable (p value) | Selected Predictors/Methods for Selecting Predictors for Multivariate Model | Interactions Considered? | Multivariate Model Results, Variable (p value) | Discrimination/Validation Methods/Results | Calibration/Goodness of Fit
HER2 Discrepant
Paik et al. 2007; Kim et al, in preparation; Romond et al. 2005
Perez et al. 2007; Perez et al. 2006; Romond et al. 2005
HER2 Negative
CALGB 9840 Seidman et al. 2004 | RCT ORR multivariate regression | | | insufficient detail in abstract or slides
CALGB 150002 Kaufman et al. 2007 | not reported

Table II-I Adverse Events

Toxicity Type | Study | Severity or Grade | Results
HER2 Discrepant (IHC 2+/FISH+)
Treatment-related mortality | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Nausea | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Vomiting | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Anorexia | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Lethargy | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Neurosensory | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Hearing loss | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Cardiac ischemia | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Diminished LVEF | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Arrhythmias | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Bronchopulmonary | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Dermatologic | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Kidney | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Anemia | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Thrombocytopenia | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Leukopenia or neutropenia | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Infection | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Other | | | F/U (mo) | Grp1 n | % | Grp2 n | %
HER2 Negative
Treatment-related mortality | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Nausea | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Vomiting | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Anorexia | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Lethargy | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Neurosensory | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Hearing loss | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Cardiac ischemia | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Diminished LVEF | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Arrhythmias | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Bronchopulmonary | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Dermatologic | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Kidney | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Anemia | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Thrombocytopenia | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Leukopenia or neutropenia | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Infection | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Other | | | F/U (mo) | Grp1 n | % | Grp2 n | %

Data Abstraction Table

Table IIIa-A Design, Enrollment and Treatment

Study | Design | Therapeutic Setting | n, Enrolled (Randomized) | n, Evaluated | n, Withdrawn (Lost to F/U) | Treatment Regimen (Agents)
Adjuvant Chemotherapy
Yang et al. 2003 rec. # 8840 | single arm retrospective series | adjuvant therapy post mastectomy | 94 (identically treated; 13 of 107 in series not given adj. chemo) | 94 (outcomes reported separately) | 0 | cyclophosphamide + methotrexate + fluorouracil (CMF)
Gusterson et al. 2003; rec. # 43690 | RCT; separate randomization by nodal status | adjuvant therapy: none versus one cycle peri-op versus prolonged | 1275 node-neg 1229 node-pos | 760 node-neg 746 node-pos | 515 node-neg 483 node-pos (no samples) | node-neg: peri-op CMF versus no adj therapy; node-pos: peri-op versus continuous CMF
Moliterni et. al. 2003; rec. # 10210 | RCT retrospective analysis by HER2 status | adjuvant therapy post mastectomy or quadrantectomy with axillary dissect. (1–3 nodes+) | 552 | 506 | 46 (HER2 status unknown) | CMF alone (12 cycles) versus CMF for 8 cycles then doxorubicin for 4 cycles (CMF→(A)
Colozza et al. 2005; rec. # 3820 | RCT retrospective analysis by HER2 status | post-operative adjuvant therapy; node- if ER/PR neg or node+ with ≤9 nodes involved | 348 | 266 | 82 (no tumor samples) | CMF for 6 cycles versus epirubicin weekly for 4 months
Pritchard et al. 2006; rec. # 1760 | RCT retrospective analysis by HER2 status | adjuvant therapy post mastectomy or lumpectomy with axillary dissection; all node+ | 710 | 634 (by IHC) 628 (by FISH) | 71 (no tumor samples) 5 (IHC & FISH failed) | CMF (Cx) versus CEF (Tx); each given for 6 cycles; no endocrine therapy after adjuvant chemoTx
Knoop et al. 2005; rec. # 3450 | RCT (2 × 2) retrospective analysis by HER2 status | adjuvant therapy post mastectomy or lumpectomy with axillary dissection | 1,195 (980 Danes eligible) | 773 (805 tested for HER2 status) | CMF: 79 of 500 CEF: 128 of 480 | CMF (Cx) versus CEF (Tx); each given for 9 cycles ± pamidronate, daily for 4 years; no adjuvant tamoxifen
Dressler et al. 2005, rec. # 4280; Thor et al. 1998, rec. # 40880 CALGB trial 8541 & lab companion study 8869 | 3-arm RCT retrospective analysis by HER2 status | adjuvant therapy post mastectomy or lumpectomy with axillary dissection; all node+ | 1,549 (in CALGB 8541) | 524 (of 993 in CALGB 8869) | 1,025 (556 not in 8869 study + 469 not in Dressler et al.) | 4 cycles high dose CAF (600/60/600 mg/m^2^) q4wk versus 6 cycles moderate dose CAF (400/40/400 mg/m^2^) q4wk versus 4 cycles low dose CAF (300/30/300 mg/m^2^) q4wk; similar proportions in each arm given 5 years of twice daily tamoxifen (41%, 40%, 34%) for ER+, post-menopausal disease
Del Mastro et al. 2004, 2005; rec. # 48020 GONO-MIG-1 trial | RCT retrospective analysis by HER2 status | adjuvant therapy for node- high-risk or node+ patients | 1,214 | 731 | 483 (specimens unavailable for HER2 testing) | 6 cycles FEC21 regimen q3wk versus up to 9 cycles FEC14 regimen q2wk (same drug doses in each regimen; ER+ & PR+ patients in each arm received tamoxifen qd for 5 years
Tanner et al. 2006; rec. # 1820 | STD-dose arm of RCT; retrospective analysis by HER2 status | adjuvant therapy post mastectomy or lumpectomy with axillary dissection | 525 (251 to STD-dose arm) | 391 (180 for STD-dose arm) | 274 (71 from STD-dose arm; no samples) | FEC (9 cycles; individualized doses based on hematological toxicity) versus HDC/AuSCS using CTCb after 3–4 cycles of FEC (did not abstract data from HDC/AuSCS arm); loco-regional RTx + 5 years of tamoxifen for all patients
Hayes et al. 2007; rec. # 47610 CALGB 9344 | subset from 3 X 2 RCT; retrospective analysis by HER2 status | adjuvant therapy for node+ patients after surgery with negative margins | 1500 (2 groups, 750 each, randomly selected from 3121 in RCT) | 1322 | 178 (no tumor specimens; 1621 RCT patients not analyzed by HER2 status) | 4 cycles of AC (randomized to 1 of 3 doxorubicin doses) followed by 4 cycles of paclitaxel or observation (a second; separately reported doxorubicin dose did not change outcomes
Martin et al. 2005; rec # 47650 | RCT pre-planned subgroups; 2^nd^ interim analysis of ongoing trial | adjuvant therapy for node+ patients after surgery with negative margins | 1491 | 1262 | 229 (no tumor specimens | 6 cycles (3 wks each) of docetaxel + doxorubicin + cyclophosphamide (DAC) versus flluorouracil + doxorubicin + cyclophosphamide (FAC); equal proportion (ER or PR)^+^ patients, each arm took qd tamoxifen for 5 years
Neoadjuvant (Pre-operative) Chemotherapy
Learn et al. 2005; rec. # 47640 | 3 arm RCT; retrospective analysis by HER2 status | pre-operative chemotherapy for operable breast cancer (T1–3, N0–1, M0) | 144 | 104 | 40 (no tumor specimen, 23; HER2 status unknown, 17) | 4 cycles AC ± docetaxel (D) q3wk, followed by surgery; 3^rd^ arm given AC + post-surgery D (pooled with AC alone controls for analysis by HER2 status); all patients given 5 yrs of TAM qd
Arriola et al. 2006; rec # 950 | prospective single-arm series | primary chemotherapy for T2–3 N0–1 operable breast cancer | 232 | 232 | 0 | doxorubicin (75 mg/m^2^) 4 cycles, q3wk, then lumpectomy or mastectomy + 3-level axillary dissect.
Park et al. 2003; rec # 9960 | retrospective single-arm series | pre-operative chemotherapy for locally-advanced disease | 67 | 67 | 0 | doxorubicin (50 mg/m^2^) 4 cycles, q3wk, prior to breast conservation or mastectomy
Zhang et al. 2003; rec # 9820 | retrospective single-arm series | pre-operative chemotherapy for operable breast cancer | 97 | 97 | 0 | FAC q3wk (6 cycles for 7 patients, 5 cycles for 1, 4 cycles for 81, and 3 cycles for 8)
Tulbah et al. 2002; rec # 11560 | retrospective single-arm series | pre-operative chemotherapy for locally-advanced, non-inflammatory breast cancer | 54 | 54 | 0 | paclitaxel + cisplatin, q3wk, for 3 or 4 cycles
Tinari et al. 2006; rec # 2300 | retrospective single-arm series | pre-operative chemotherapy for operable breast cancer | 77 (selected; 16 ineligible of 93 consecutive) | 77 | 0 | FEC q3wk (median 4 cycles; range 3–6 cycles)
Chemotherapy for Advanced or Metastatic Disease
Harris et al 2006^1^; rec. # 390, no data on no. of sites, 1994-? | RCT/RET; CALGB 9342 | Advanced (Stage IV or inoperable); first or second line Tx. No concurrent hormonal therapy | 474 | 165 (of n=175 w adequate tumor blocks; n= 10, all bio-marker tests unsuccessful) | 299 (n=273, no blocks; n=26, blocks inadequate); similar characteristics & outcomes, w/wo blocks, except DFS | Paclitaxel; compared 3 doses—175, 210, or 250 mg/m^2^ q3wk to failure (progression or intolerable toxocity)—but data combined for this analysis)
Di Leo et al 2004; rec. # 5970; 29 of 41 sites in original trial, 7/94–1/97^2^ | Phase III RCT (not blinded); TAX 303 trial; secondary analysis | Metastatic disease; first or second line therapy; prior CMF required (adj or for mets); prior anthraciclines or taxanes excluded | 326 | 176 | 150 (n=74, Grp1; n=76, Grp 2) | Grp 1: doxorubicin (75 mg/m^2^) (A; n=91) vs Grp 2: docetaxel (100 mg/m^2^) (T; n=85) every 3 wks; max 7 cycles absent progression or toxicity. No stat sig differences between populations with versus without specimens for HER2 analysis.
Konecny et al 2004; rec. # 6740; ~71 sites, Germany, 10/96–12/99 | RCT; secondary analysis | Metastatic; no prior chemo for metastatic disease, no metastasis to CNS or to bone only. Stratified by 0 vs 1 prior hormonal Tx for metastatic disease. | 579 enrolled; 516 eligible were randomized & treated | 275 | 241 (n=219, no block; n=17, technically inadequate; n=5, no invasive cancer; no SS diffs between pts w/wo known HER2 status. | Grp 1: epirubicin (60 mg/m^2^) and cyclophosphamide (600 mg/m^2^) (EC, n=137); Grp 2: epirubicin (60 mg/m^2^) and paclitaxel (175 mg/m^2^)(ET, n=138). Chemo given q3 wks for max of 10 cycles; median=6 cycles.

1 Some data from: Winer EP. Berry DA. Woolf S. Duggan D. Kornblith A. Harris LN. Michaelson RA. Kirshner JA. Fleming GF. Perry MC. Graham ML. Sharp SA. Keresztes R. Henderson IC. Hudis C. Muss H. Norton L. Failure of higher-dose paclitaxel to improve outcome in patients with metastatic breast cancer: cancer and leukemia group B trial 9342. J Clin Oncol 22(11):2061–8, 2004 Jun 1.

2 Some data from: Chan S, Friedrichs K, Noel D et al. Prospective randomized trial of docetaxel versus doxorubicin in patients with metastatic breast cancer. J Clin Oncol 1999;17(8):2341–54.

Table IIIa-B Patient Characteristics

Study | Age | | | Race (%) | | | Disease Stage | | | Disease Stage | | | | Performance Status | | | Hormone Receptor Status
Adjuvant Chemotherapy
Yang et al. 2003 rec. # 8840 (of n=107 tested for expression of various markers) | mn | | | | | | | Grp1 | Grp2 | | | | | Scale | not reported
Yang et al. 2003 rec. # 8840 (of n=107 tested for expression of various markers) | md | 51.9 yrs | | B | | | I | | | T <3cm | 31 (33%) | | | | | | ER+ | not reported
Yang et al. 2003 rec. # 8840 (of n=107 tested for expression of various markers) | rng | 33–77 yrs | | W | | | IIa | | | T 3–5cm | 39 (41%) | | | | | | PR+
Yang et al. 2003 rec. # 8840 (of n=107 tested for expression of various markers) | sd | | | H | | | IIb | not reported | | T3 >5 cm | 24 (26%)
Yang et al. 2003 rec. # 8840 (of n=107 tested for expression of various markers) | <50 yrs | 45 (47.9%) | | A | 100% | | IIIa | | | N- | 41 (38%)
Yang et al. 2003 rec. # 8840 (of n=107 tested for expression of various markers) | ≥50 yrs | 49 (52.1%) | | O | | | IIIb | | | N+ | 66 (62%)
| | | | | | IV
Gusterson et al. 2003; rec. # 43690 760 node- pts randomized to periop CMF vs no adj. Tx | | HER2+ | HER2- | | Grp1 | Grp2 | | Grp1 | Grp2 | | HER2+ | HER2- | | Scale | not reported | | | HER2+ | HER2-
Gusterson et al. 2003; rec. # 43690 760 node- pts randomized to periop CMF vs no adj. Tx | mn | | | B | | | I | | | Mn T | | | | | | | ER+ | 36% | 51%
Gusterson et al. 2003; rec. # 43690 760 node- pts randomized to periop CMF vs no adj. Tx | md | | | W | not reported | | IIa | | | T size | | | | | | | ER- | 41% | 32%
Gusterson et al. 2003; rec. # 43690 760 node- pts randomized to periop CMF vs no adj. Tx | rng | | | H | | | IIb | not reported | | ≤2cm | 41% | 57% | | | | | unk | 23% | 17%
Gusterson et al. 2003; rec. # 43690 760 node- pts randomized to periop CMF vs no adj. Tx | sd | | | A | | | IIIa | | | >2cm | 53% | 40% | | | | | PR+ | 24% | 37.5%
Gusterson et al. 2003; rec. # 43690 760 node- pts randomized to periop CMF vs no adj. Tx | menopausal status: | | | O | | | IIIb | | | unk | 6% | 3% | | | | | PR- | 50% | 37.5%
Gusterson et al. 2003; rec. # 43690 760 node- pts randomized to periop CMF vs no adj. Tx | pre- | 52.5% | 53% | | | | IV | | | N0 | 100% | 100% | | | | | unk | 26% | 25%
post- | 47.5% | 47%
Gusterson et al. 2003; rec. # 43690 746 node+ pts randomized to perioperative vs prolonged CMF | | HER2+ | HER2- | | Grp1 | Grp2 | | Grp1 | Grp2 | | HER2+ | HER2- | | Scale | not reported | | | HER2+ | HER2-
Gusterson et al. 2003; rec. # 43690 746 node+ pts randomized to perioperative vs prolonged CMF | mn | | | B | | | I | | | Mn T | | | | | | | ER+ | 56% | 28%
Gusterson et al. 2003; rec. # 43690 746 node+ pts randomized to perioperative vs prolonged CMF | md | | | W | not reported | | IIa | | | T size | | | | | | | ER- | 32% | 59%
Gusterson et al. 2003; rec. # 43690 746 node+ pts randomized to perioperative vs prolonged CMF | rng | | | H | | | IIb | not reported | | ≤2cm | not reported | | | | | | unk | 12% | 13%
Gusterson et al. 2003; rec. # 43690 746 node+ pts randomized to perioperative vs prolonged CMF | sd | | | A | | | IIIa | | | >2cm | | | | | | | PR+ | 62% | 36%
Gusterson et al. 2003; rec. # 43690 746 node+ pts randomized to perioperative vs prolonged CMF | menopausal status: | | | O | | | IIIb | | | # positive nodes: | | | | | | | PR- | 22% | 45%
Gusterson et al. 2003; rec. # 43690 746 node+ pts randomized to perioperative vs prolonged CMF | pre- | 50% | 60% | | | | IV | | | 1–3+ | 51% | 57% | | | | | unk | 16% | 19%
post- | 50% | 40% | | | | | | | ≥4 | 49% | 43%
Moliterni et. al. 2003; rec. # 10210 RCT; CMF (Grp 1) versus CMF→A (Grp 2) | | Grp1 | Grp2 | | Grp1 | Grp2 | | Grp1 | Grp2 | | Grp1 | Grp2 | | Scale | not reported | | | Grp1 | Grp2
Moliterni et. al. 2003; rec. # 10210 RCT; CMF (Grp 1) versus CMF→A (Grp 2) | mn | | | B | | | I | | | Mn T | | | | | | | ER+ | 59% | 52%
Moliterni et. al. 2003; rec. # 10210 RCT; CMF (Grp 1) versus CMF→A (Grp 2) | md | not reported | | W | not reported | | IIa | | | T stage distribution not reported | | | | | | | ER- | 34% | 39%
Moliterni et. al. 2003; rec. # 10210 RCT; CMF (Grp 1) versus CMF→A (Grp 2) | rng | | | H | | | IIb | not reported | | ~65% <2.1 cm diam. | | | | | | | unk | 7% | 9%
Moliterni et. al. 2003; rec. # 10210 RCT; CMF (Grp 1) versus CMF→A (Grp 2) | sd | | | A | | | IIIa | | | N0 | | | | | | | PR+ | 53% | 53%
Moliterni et. al. 2003; rec. # 10210 RCT; CMF (Grp 1) versus CMF→A (Grp 2) | <51 yr | 69% | 67% | O | | | IIIb | | | N1 | 100% | 100% | | | | | PR- | 38% | 34%
| | | | | | IV | | | N2 | | | | | | | unk | 9% | 13%
Colozza et al. 2005; rec. # 3820 RCT; CMF (Grp 1) vs epirubicin (Grp 2); n=133 each tested for HER2 status | | Grp1 | Grp2 | | Grp1 | Grp2 | | Grp1 | Grp2 | | Grp1 | Grp2 | | Scale | not reported | | | Grp1 | Grp2
Colozza et al. 2005; rec. # 3820 RCT; CMF (Grp 1) vs epirubicin (Grp 2); n=133 each tested for HER2 status | age (years): | | | B | | | I | | | tumor diameter (cm): | | | | | | | ER+ | 56% | 55%
Colozza et al. 2005; rec. # 3820 RCT; CMF (Grp 1) vs epirubicin (Grp 2); n=133 each tested for HER2 status | <40 | 12 | 9 | W | not reported | | IIa | | | ≤2 | 45% | 46% | | | | | ER- | 41% | 44%
Colozza et al. 2005; rec. # 3820 RCT; CMF (Grp 1) vs epirubicin (Grp 2); n=133 each tested for HER2 status | 40–50 | 32 | 40 | H | | | IIb | not reported | | 2–5 | 50% | 48% | | | | | unk | 4% | 2%
Colozza et al. 2005; rec. # 3820 RCT; CMF (Grp 1) vs epirubicin (Grp 2); n=133 each tested for HER2 status | >50 | 56 | 51 | A | | | IIIa | | | >5 | 1% | 0% | | | | | PR+ | 63% | 63%
Colozza et al. 2005; rec. # 3820 RCT; CMF (Grp 1) vs epirubicin (Grp 2); n=133 each tested for HER2 status | menopausal status: | | | O | | | IIIb | | | unk | 5% | 6% | | | | | PR- | 33% | 35%
Colozza et al. 2005; rec. # 3820 RCT; CMF (Grp 1) vs epirubicin (Grp 2); n=133 each tested for HER2 status | pre | 53 | 53 | | | | IV | | | N0 | 20% | 23% | | | | | unk | 4% | 2%
Colozza et al. 2005; rec. # 3820 RCT; CMF (Grp 1) vs epirubicin (Grp 2); n=133 each tested for HER2 status | post | 47 | 47 | | | | | | | N1–3 | 59% | 52%
| | | | | | | | | N4–9 | 21% | 26%
Pritchard et al. 2006; rec. # 1760 RCT; CMF versus CEF; n=163 FISH^+^ (Grp 1); n=465 FISH^-^ (Grp2) | | Grp1 | Grp2 | | Grp1 | Grp2 | | Grp1 | Grp2 | | Grp1 | Grp2 | | Scale | not reported | | | Grp1 | Grp2
Pritchard et al. 2006; rec. # 1760 RCT; CMF versus CEF; n=163 FISH^+^ (Grp 1); n=465 FISH^-^ (Grp2) | age (%) | | | B | | | I | | | T1 | 35% | 40% | | | | | ER+ | 56% | 62%
Pritchard et al. 2006; rec. # 1760 RCT; CMF versus CEF; n=163 FISH^+^ (Grp 1); n=465 FISH^-^ (Grp2) | ≤29 yr | 4 | 1 | W | not reported | | IIa | | | T2 | 52% | 49% | | | | | ER- | 35% | 27%
Pritchard et al. 2006; rec. # 1760 RCT; CMF versus CEF; n=163 FISH^+^ (Grp 1); n=465 FISH^-^ (Grp2) | 30–39 | 27 | 22 | H | | | IIb | not reported | | T3 | 5% | 5% | | | | | unk | 9% | 12%
Pritchard et al. 2006; rec. # 1760 RCT; CMF versus CEF; n=163 FISH^+^ (Grp 1); n=465 FISH^-^ (Grp2) | 40–49 | 54 | 60 | A | | | IIIa | | | # positive nodes: | | | | | | | PR+ | not reported
Pritchard et al. 2006; rec. # 1760 RCT; CMF versus CEF; n=163 FISH^+^ (Grp 1); n=465 FISH^-^ (Grp2) | ≥50 yr | 15 | 17 | O | | | IIIb | | | 0 | 0 | 0
Pritchard et al. 2006; rec. # 1760 RCT; CMF versus CEF; n=163 FISH^+^ (Grp 1); n=465 FISH^-^ (Grp2) | all pre-menopausal; ineligible if post-menopausal | | | | | | IV | | | 1–3 | 57% | 63%
Pritchard et al. 2006; rec. # 1760 RCT; CMF versus CEF; n=163 FISH^+^ (Grp 1); n=465 FISH^-^ (Grp2) | | | | | | | | | | 4–10 | 36% | 31%
| | | | | | | | | ≤10 | 7% | 7%
Knoop et al. 2005; rec. # 3450 RCT (n=773); CMF (Grp 1; n=421) vs CEF (Grp 2; n=352) | | Grp1 | Grp2 | | Grp1 | Grp2 | | Grp1 | Grp2 | | Grp1 | Grp2 | | Scale | not reported | | | Grp1 | Grp2
Knoop et al. 2005; rec. # 3450 RCT (n=773); CMF (Grp 1; n=421) vs CEF (Grp 2; n=352) | age in years (%) | | | B | | | I | | | T size, cm (%) | | | | | | | | (%) | (%)
Knoop et al. 2005; rec. # 3450 RCT (n=773); CMF (Grp 1; n=421) vs CEF (Grp 2; n=352) | <40 | | 16.4 | W | not reported | | IIa | | | 0–2 | 42.4 | 39.3 | | | | | ER+ | 27.1 | 25
Knoop et al. 2005; rec. # 3450 RCT (n=773); CMF (Grp 1; n=421) vs CEF (Grp 2; n=352) | 40–49 | | 47.6 | H | | | IIb | not reported | | 2.1–5 | 49.5 | 52.4 | | | | | ER- | 66.7 | 68.2
Knoop et al. 2005; rec. # 3450 RCT (n=773); CMF (Grp 1; n=421) vs CEF (Grp 2; n=352) | 50–59 | | 22.0 | A | | | IIIa | | | >5 | 8.1 | 8.3 | | | | | PR+ | not reported
Knoop et al. 2005; rec. # 3450 RCT (n=773); CMF (Grp 1; n=421) vs CEF (Grp 2; n=352) | 60–69 | | 14.0 | O | | | IIIb | | | # positive nodes (%) | | | | | | | PR-
Knoop et al. 2005; rec. # 3450 RCT (n=773); CMF (Grp 1; n=421) vs CEF (Grp 2; n=352) | menopausal status | | | | | | IV | | | 0 | 35.6 | 37.8
Knoop et al. 2005; rec. # 3450 RCT (n=773); CMF (Grp 1; n=421) vs CEF (Grp 2; n=352) | pre | 69.8 | 68.5 | | | | | | | 1–3 | 33.3 | 29.5
post | 30.2 | 31.5 | | | | | | | >3 | 31.3 | 32.7
Dressler et al. 2005, rec. # 4280; Thor et al. 1998, rec. # 40880; Grp 1, n=542, Dressler analysis; Grp 2, n=469, rest of CALGB 8869^3^ | | Grp1 | Grp2 | | Grp1 | Grp2 | | Grp1 | Grp2 | | Grp1 | Grp2 | | Scale | not reported | | | Grp1 | Grp2
Dressler et al. 2005, rec. # 4280; Thor et al. 1998, rec. # 40880; Grp 1, n=542, Dressler analysis; Grp 2, n=469, rest of CALGB 8869^3^ | mn | 50.6 yr | 50.4 yr | B | | | I | | | Mn T | 2.96 | 2.86 | | | | | | (%) | (%)
Dressler et al. 2005, rec. # 4280; Thor et al. 1998, rec. # 40880; Grp 1, n=542, Dressler analysis; Grp 2, n=469, rest of CALGB 8869^3^ | md | | | W | not reported | | IIa | | | (cm) | | | | | | | ER+ | 68.2 | 64.8
Dressler et al. 2005, rec. # 4280; Thor et al. 1998, rec. # 40880; Grp 1, n=542, Dressler analysis; Grp 2, n=469, rest of CALGB 8869^3^ | rng | | | H | | | IIb | not reported | | Mn # | 4.62 | 4.68
Dressler et al. 2005, rec. # 4280; Thor et al. 1998, rec. # 40880; Grp 1, n=542, Dressler analysis; Grp 2, n=469, rest of CALGB 8869^3^ | pre- | 40.7 | 40.3 | A | | | IIIa | | | N^+^ | | | | | | | PR+ | 59.1 | 55.7
Dressler et al. 2005, rec. # 4280; Thor et al. 1998, rec. # 40880; Grp 1, n=542, Dressler analysis; Grp 2, n=469, rest of CALGB 8869^3^ | | | | O | | | IIIb
| | | | | | IV
Del Mastro et al. 2004, 2005; rec # 48020 Grp 1: n=731, HER2 known Grp 2: n=483 HER2 unknown | | Grp1 | Grp2 | | Grp1 | Grp2 | | Grp1 | Grp2 | | Grp1 | Grp2 | | Scale | not reported | | | Grp1 | Grp2
Del Mastro et al. 2004, 2005; rec # 48020 Grp 1: n=731, HER2 known Grp 2: n=483 HER2 unknown | md | 54 | 54 | B | | | I | | | T1 | 47.1% | 52.6% | | | | | ER+ | 54% | 49%
Del Mastro et al. 2004, 2005; rec # 48020 Grp 1: n=731, HER2 known Grp 2: n=483 HER2 unknown | rng | 25–70 | 26–70 | W | not reported | | IIa | | | T2 | 46.2% | 42.2% | | | | | ER- | 43% | 38%
Del Mastro et al. 2004, 2005; rec # 48020 Grp 1: n=731, HER2 known Grp 2: n=483 HER2 unknown | <50 | 35.8% | 43.1% | H | | | IIb | not reported | | T3–4 | 5.3% | 4.4% | | | | | ER? | 3% | 13%
Del Mastro et al. 2004, 2005; rec # 48020 Grp 1: n=731, HER2 known Grp 2: n=483 HER2 unknown | 50–59 | 34.7% | 35.6% | A | | | IIIa | | | T? | 1.4% | 0.8% | | | | | PR+ | 42% | 36%
Del Mastro et al. 2004, 2005; rec # 48020 Grp 1: n=731, HER2 known Grp 2: n=483 HER2 unknown | >59 | 29.5% | 21.3% | O | | | IIIb | | | N+ | 62.3% | 67.7% | | | | | PR- | 50% | 44%
| | | | | | IV | | | N- | 37.6% | 32.3% | | | | | PR? | 8% | 20%
Tanner et al. 2006; rec. # 1820 (n=391 tested for HER2 status; 180 from FEC arm + 211 from CTCb arm) | | HER2+ | HER2- | | Grp1 | Grp2 | | Grp1 | Grp2 | | n | HER2^+^ | HER2^-^ | Scale | not reported | | | HER2^+^ | HER2^-^
Tanner et al. 2006; rec. # 1820 (n=391 tested for HER2 status; 180 from FEC arm + 211 from CTCb arm) | <50 years of age: | | | B | | | I | | | tumor size: | | | | | | | ER+ and/or PR+:
Tanner et al. 2006; rec. # 1820 (n=391 tested for HER2 status; 180 from FEC arm + 211 from CTCb arm) | n=227 | 30.8% | 69.2% | W | not reported | | IIa | | | <2 cm | 126 | 27% | 73% | | | | yes (210) | 22% | 78%
Tanner et al. 2006; rec. # 1820 (n=391 tested for HER2 status; 180 from FEC arm + 211 from CTCb arm) | ≥50 years of age | | | H | | | IIb | not reported | | 2–5cm | 213 | 36% | 64% | | | | no (148) | 49% | 51%
Tanner et al. 2006; rec. # 1820 (n=391 tested for HER2 status; 180 from FEC arm + 211 from CTCb arm) | n=164 | 35.4% | 64.6% | A | | | IIIa | | | >5 cm | 37 | 30% | 70% | | | | unk (33) | 27% | 73%
Tanner et al. 2006; rec. # 1820 (n=391 tested for HER2 status; 180 from FEC arm + 211 from CTCb arm) | | | | O | | | IIIb | | | unk | 15 | 47% | 53%
Tanner et al. 2006; rec. # 1820 (n=391 tested for HER2 status; 180 from FEC arm + 211 from CTCb arm) | | | | | | | IV | | | # positive nodes:
Tanner et al. 2006; rec. # 1820 (n=391 tested for HER2 status; 180 from FEC arm + 211 from CTCb arm) | | | | | | | | | | 5–7 | 68 | 34% | 66%
Tanner et al. 2006; rec. # 1820 (n=391 tested for HER2 status; 180 from FEC arm + 211 from CTCb arm) | | | | | | | | | | 8–9 | 107 | 27% | 73%
| | | | | | | | | ≥10 | 216 | 35% | 65%
Hayes et al. 2007; rec. # 47610 Grp1, n=643 Grp2, n=679 each is random mix of patients from 6 RCT arms^4^ | | Grp1 | Grp2 | | Grp1 | Grp2 | | Grp1 | Grp2 | | Grp1 | Grp2 | | Scale | not reported | | | Grp1 | Grp2
Hayes et al. 2007; rec. # 47610 Grp1, n=643 Grp2, n=679 each is random mix of patients from 6 RCT arms^4^ | age, years: | | | B | 8% | 9% | I | | | tumor size (cm): | | | | | | | ER+ | 57% | 62%
Hayes et al. 2007; rec. # 47610 Grp1, n=643 Grp2, n=679 each is random mix of patients from 6 RCT arms^4^ | <40 | 20% | 20% | W | 84% | 84% | IIa | | | ≤2 | 33% | 35% | | | | | ER- | 43% | 38%
Hayes et al. 2007; rec. # 47610 Grp1, n=643 Grp2, n=679 each is random mix of patients from 6 RCT arms^4^ | 40–49 | 40% | 38% | H | 5% | 4% | IIb | not reported | | >2 | 66% | 64% | | | | | PR+ | not reported
Hayes et al. 2007; rec. # 47610 Grp1, n=643 Grp2, n=679 each is random mix of patients from 6 RCT arms^4^ | 50–59 | 27% | 30% | A | 2% | 2% | IIIa | | | unk | <1% | <1%
Hayes et al. 2007; rec. # 47610 Grp1, n=643 Grp2, n=679 each is random mix of patients from 6 RCT arms^4^ | ≥60 | 12% | 12% | O | 1% | 1% | IIIb | | | # positive nodes:
Hayes et al. 2007; rec. # 47610 Grp1, n=643 Grp2, n=679 each is random mix of patients from 6 RCT arms^4^ | menopausal status: | | | | | | IV | | | 1–3 | 48% | 46%
Hayes et al. 2007; rec. # 47610 Grp1, n=643 Grp2, n=679 each is random mix of patients from 6 RCT arms^4^ | pre | 61% | 61% | | | | | | | 4–9 | 40% | 43%
post | 39% | 39% | | | | | | | ≥10 | 12% | 11%
Martin et al. 2005; rec # 47650 Grp 1: DAC, n=745 Grp 2: FAC, n=746 | | Grp1 | Grp2 | | Grp1 | Grp2 | | Grp1 | Grp2 | | Grp1 | Grp2 | | Scale | Grp1 | Grp2 | | Grp1 | Grp2
Martin et al. 2005; rec # 47650 Grp 1: DAC, n=745 Grp 2: FAC, n=746 | mn | | | B | | | I | | | T1 | 40% | 43% | | 100% had Karnofsky score ≥80% | | | ER+ &/or
Martin et al. 2005; rec # 47650 Grp 1: DAC, n=745 Grp 2: FAC, n=746 | md | 49 | 49 | W | not reported | | IIa | | | T2 | 52% | 51% | | | | | PR+ | 76% | 76%
Martin et al. 2005; rec # 47650 Grp 1: DAC, n=745 Grp 2: FAC, n=746 | rng | 26–70 | 23–70 | H | | | IIb | not reported | | T3 | 8% | 6% | | | | | menopausal status:
Martin et al. 2005; rec # 47650 Grp 1: DAC, n=745 Grp 2: FAC, n=746 | sd | | | A | | | IIIa | | | N0 | 0 | 0 | | | | | pre: | 56% | 55%
Martin et al. 2005; rec # 47650 Grp 1: DAC, n=745 Grp 2: FAC, n=746 | | | | O | | | IIIb | | | 1–3N^+^ | 63% | 62% | | | | | post: | 44% | 45%
| | | | | | IV | | | ≥4 N^+^ | 37% | 38%
Neoadjuvant (Pre-operative) Chemotherapy
Learn et al. 2005; rec. # 47640 AC, n=50 AC+D, n=47 AC→D, n=47 pooled data on n=142 evaluated for clin. response | mn | 48 yrs | | B | | | I | | 23.6% | clinical tumor diameter | | | | Scale | not reported | | Of n=121 with biopsy specimens available for IHC:
Learn et al. 2005; rec. # 47640 AC, n=50 AC+D, n=47 AC→D, n=47 pooled data on n=142 evaluated for clin. response | md | 47 yrs | | W | | | IIa | | 39.6% | ≤2 cm | 28.2% | | | | | | ER+ | 60.3%
Learn et al. 2005; rec. # 47640 AC, n=50 AC+D, n=47 AC→D, n=47 pooled data on n=142 evaluated for clin. response | rng | 27–73 yrs | | H | 71% | | IIb | | 30.6% | >2-≤5 cm | 47.2% | | | | | | ER- | 39.7%
Learn et al. 2005; rec. # 47640 AC, n=50 AC+D, n=47 AC→D, n=47 pooled data on n=142 evaluated for clin. response | sd | | | A | | | IIIa | | 6.3% | >5 cm | 24.6% | | | | | | PR+ | 57.9%
Learn et al. 2005; rec. # 47640 AC, n=50 AC+D, n=47 AC→D, n=47 pooled data on n=142 evaluated for clin. response | | | | O | | | IIIb | | 0 | N0 | 61.3% | | | | | | PR- | 42.1%
Learn et al. 2005; rec. # 47640 AC, n=50 AC+D, n=47 AC→D, n=47 pooled data on n=142 evaluated for clin. response | | | | not reported | 29% | | IV | | 0 | N1 | 38.7%
| | | | | | | | | N≥2 | 0
Arriola et al. 2006; rec # 950 prospective single-arm series; n=232 | mn | 47 yrs | | B | | | I | | | T2 | 30% | | | Scale | not reported | | ER+ | 67%
Arriola et al. 2006; rec # 950 prospective single-arm series; n=232 | md | | | W | | | IIa | | | T3 | 70% | | | | | | ER- | 29%
Arriola et al. 2006; rec # 950 prospective single-arm series; n=232 | rng | | | H | not reported | | IIb | not reported | | N0 | 60% | | | | | | unk | 4%
Arriola et al. 2006; rec # 950 prospective single-arm series; n=232 | sd | | | A | | | IIIa | | | N1 | 40% | | | | | | PR+ | 52%
Arriola et al. 2006; rec # 950 prospective single-arm series; n=232 | | | | O | | | IIIb | | | | | | | | | | PR- | 43%
| | | | | | IV | | | | | | | | | | unk | 5%
Park et al. 2003; rec # 9960 retrospective single-arm series; n=67 | years | | | B | | | I | | | tumor size (cm):
Park et al. 2003; rec # 9960 retrospective single-arm series; n=67 | <50 | | 82% | W | | | IIa | | | 5–10 | 91% | | | Scale | not reported | | ER+ | 46%
Park et al. 2003; rec # 9960 retrospective single-arm series; n=67 | ≥50 | | 18% | H | not reported | | IIb | not reported | | >10 | 9% | | | | | | ER- | 54%
Park et al. 2003; rec # 9960 retrospective single-arm series; n=67 | | | | 0 | | | IIIa | | | | | | | | | | PR status not reported
| | | | | | IV
Zhang et al. 2003; rec # 9820 retrospective single-arm series; n=97 | md | 44.5 yr | | B | | | I | | | T1 | 13% | | | Scale | not reported | | ER+ | 65%
Zhang et al. 2003; rec # 9820 retrospective single-arm series; n=97 | rng | 25–74 yr | | W | not reported | | IIa | | | T2 | 53% | | | | | | PR+ | 56%
Zhang et al. 2003; rec # 9820 retrospective single-arm series; n=97 | sd | | | H | | | IIb | not reported | | ≥T3 | 34%
Zhang et al. 2003; rec # 9820 retrospective single-arm series; n=97 | ≥50 | 44% | | A | | | IIIa | | | N^-^ | 33%
Zhang et al. 2003; rec # 9820 retrospective single-arm series; n=97 | <50 | 56% | | O | | | IIIb | | | N^+^ | 67%
| | | | | | IV
Tulbah et al. 2002; rec # 11560 | | HER2^+^ | HER2^-^ | B | | | | HER2^+^ | HER2^-^ | | HER2^+^ | HER2^-^ | | Scale | not reported | | | HER2^+^ | HER2^-^
Tulbah et al. 2002; rec # 11560 | age (yr) | | | W | not reported | | I | 0 | 0 | T2 | 3 | 7 | | | | | ER+ | 12 | 16
Tulbah et al. 2002; rec # 11560 | ≥50 | 20 | 27 | H | | | IIa | 1 | 3 | T3 | 9 | 16 | | | | | ER- | 9 | 11
Tulbah et al. 2002; rec # 11560 | >50 | 2 | 5 | A | | | IIb | 6 | 9 | T4 | 10 | 9 | | | | | unk | 1 | 5
Tulbah et al. 2002; rec # 11560 | menopausal status: | | | O | | | IIIa | 5 | 10 | N0 | 8 | 9 | | | | | PR+ | 11 | 11
Tulbah et al. 2002; rec # 11560 | pre | 20 | 25 | | | | IIIb | 10 | 10 | N1 | 12 | 18 | | | | | PR- | 10 | 16
post | 2 | 7 | | | | IV | 0 | 0 | N2 | 2 | 5 | | | | | unk | 1 | 5
Tinari et al. 2006; rec # 2300 retrospective single-arm series; n=77 | mn | | | B | | | I | | | tumor size (cm): | | | | | | | ER+ | 62%
Tinari et al. 2006; rec # 2300 retrospective single-arm series; n=77 | md | 46.1 yrs | | W | not reported | | IIa | | | 2–5 | 75% | | | Scale | not reported | | ER- | 38%
Tinari et al. 2006; rec # 2300 retrospective single-arm series; n=77 | rng | 25.5–73.7 yrs | | H | | | IIb | not reported | | >5 | 25% | | | | | | PR+ | 45%
Tinari et al. 2006; rec # 2300 retrospective single-arm series; n=77 | sd | | | A | | | IIIa | | | | | | | | | | PR- | 55%
Tinari et al. 2006; rec # 2300 retrospective single-arm series; n=77 | | | | O | | | IIIb
| | | | | | IV
Chemotherapy for Advanced or Metastatic Disease
Harris et al 2006; rec. # 390 | | All | | | All | | | All | | | All | | | Scale | All | | | All
Harris et al 2006; rec. # 390 | mn | | | B | 20.6^†^ | | I | | | T1 | | | | ECOG performance status of 0,1,2=100 | | | ER+ and/or PR+=58^†^
Harris et al 2006; rec. # 390 | md | 54.9^†^ | | W | | | II | | | T2
Harris et al 2006; rec. # 390 | rng | | | H | | | III | not reported | | T3
Harris et al 2006; rec. # 390 | sd | | | A | | | IV | | | T4
Harris et al 2006; rec. # 390 | pre | | | O | | | Unk | | | N0
Harris et al 2006; rec. # 390 | post | | | | | | | | | N1
Harris et al 2006; rec. # 390 | | | | | | | | | | N2
Harris et al 2006; rec. # 390 | | | | | | | | | | N3
| | | | | | | | | median # mets: 1^†^
Di Leo et al 2004; rec. # 5970 Grp 1: A, n=91 Grp 2: T, n=85 patients with tumor blocks tested for HER2 status | | Grp1 | Grp2 | | Grp1 | Grp2 | | Grp1 | Grp2 | | Grp1 | Grp2 | | Scale | Grp1 | Grp2 | | Grp1 | Grp2
Di Leo et al 2004; rec. # 5970 Grp 1: A, n=91 Grp 2: T, n=85 patients with tumor blocks tested for HER2 status | mn | | | B | not reported | | I | | | ≥3 sites | 46% | 51% | | Karnofsky | | | ER+ | not reported
Di Leo et al 2004; rec. # 5970 Grp 1: A, n=91 Grp 2: T, n=85 patients with tumor blocks tested for HER2 status | md | 54 yr | 51yr | W | | | II | | | Visceral Involvement | 79% | 76% | | all w specimens: | | | PR+ | not reported
Di Leo et al 2004; rec. # 5970 Grp 1: A, n=91 Grp 2: T, n=85 patients with tumor blocks tested for HER2 status | rng | | | H | | | III | | | | | | | 60–70: | 15% | 15% | reported (data not shown) other factors similar in HER2 status subgroups of each arm
Di Leo et al 2004; rec. # 5970 Grp 1: A, n=91 Grp 2: T, n=85 patients with tumor blocks tested for HER2 status | sd | | | A | | | IV | 100% | 100% | | | | | ≥80 | 85% | 85%
Di Leo et al 2004; rec. # 5970 Grp 1: A, n=91 Grp 2: T, n=85 patients with tumor blocks tested for HER2 status | pre | | | O | | | Unk | | | | | | | HER2+ subgroup:
post | | | | | | | | | | | | | 60–70: | 33% | 0
Konecny et al 2004; rec. # 6740 Grp 1: EC, n=137 Grp 2: ET, n=138 data are for subgroups with known HER2 status | | Grp1 | Grp2 | | Grp1 | Grp2 | | Grp1 | Grp2 | | Grp1 | Grp2 | | Scale | Grp1 | Grp2 | | Grp1 | Grp2
Konecny et al 2004; rec. # 6740 Grp 1: EC, n=137 Grp 2: ET, n=138 data are for subgroups with known HER2 status | Mn | 55 | 55 | B | | | I | | | Nuclear Grade | | | | Karnofsky | | | ER+ | 52.6 | 60.9
Konecny et al 2004; rec. # 6740 Grp 1: EC, n=137 Grp 2: ET, n=138 data are for subgroups with known HER2 status | md | | | W | Not reported | | II | | | 1 | 2.2 | 2.9 | | >60 | 100 | 100 | ER- | 37.2 | 32.6
Konecny et al 2004; rec. # 6740 Grp 1: EC, n=137 Grp 2: ET, n=138 data are for subgroups with known HER2 status | rng | 31–74 | 29–75 | H | | | III | | | 2 | 41.6 | 37.0 | | Prior adj chemo | | | unk | 10.2 | 6.5
Konecny et al 2004; rec. # 6740 Grp 1: EC, n=137 Grp 2: ET, n=138 data are for subgroups with known HER2 status | sd | | | A | | | IV | 100% | 100% | 3 | 38.7 | 46.3 | | Yes | 40.2 | 32.6 | PR+ | 48.9 | 49.3
Konecny et al 2004; rec. # 6740 Grp 1: EC, n=137 Grp 2: ET, n=138 data are for subgroups with known HER2 status | pre | | | O | | | Unk | | | Unk | 17.5 | 13.8 | | No | 59.1 | 65.9 | PR- | 40.1 | 42.7
Konecny et al 2004; rec. # 6740 Grp 1: EC, n=137 Grp 2: ET, n=138 data are for subgroups with known HER2 status | post | | | | | | | | | # of met sites | | | | unk | 0.7 | 1.5 | unk | 11.0 | 8.0
Konecny et al 2004; rec. # 6740 Grp 1: EC, n=137 Grp 2: ET, n=138 data are for subgroups with known HER2 status | | | | | | | | | | 1 | 35.8 | 31.9 | | Prior palliative hormone therapy
Konecny et al 2004; rec. # 6740 Grp 1: EC, n=137 Grp 2: ET, n=138 data are for subgroups with known HER2 status | | | | | | | | | | 2 | 21.2 | 21.0
Konecny et al 2004; rec. # 6740 Grp 1: EC, n=137 Grp 2: ET, n=138 data are for subgroups with known HER2 status | | | | | | | | | | ≥3 | 42.3 | 42.0 | | Yes | 14.6 | 13.8
Konecny et al 2004; rec. # 6740 Grp 1: EC, n=137 Grp 2: ET, n=138 data are for subgroups with known HER2 status | | | | | | | | | | Unk | 0.7 | 5.1 | | No | 84.7 | 86.2
| | | | | | | | | | | | | unk | 0.7 | 0

3 Also showed patient populations were similar in 3 CAF dose arms (high, moderate, low); data not abstracted here.

4 Also reported data comparing groups 1 and 2 with 1799 patients from CALGB 9344 not included in biomarker analysis; data showed similar baseline characteristics and 5-year outcomes.

* p<.05;

† characteristics of subset with biomarker data, n=165, similar to those of patients w/o biomarker measurements, n=299

Table IIIa-C HER2 Measurement Methods

Study | Assays (Name) | | Criteria for Positivity | | Test Results (%) | | Comments
Adjuvant Chemotherapy
Yang et al. 2003 rec. # 8840 | FISH | not done | FISH | not done | Pos | 36% | HER2+ = IHC3+ by DAKO scoring pre-ASCO/CAP
Yang et al. 2003 rec. # 8840 | IHC | Neomarker antibody | | | Equiv | 0 | HER2+ = IHC3+ by DAKO scoring pre-ASCO/CAP
Yang et al. 2003 rec. # 8840 | | | | | Neg | 64% | HER2+ = IHC3+ by DAKO scoring pre-ASCO/CAP
Yang et al. 2003 rec. # 8840 | | | IHC | strong & complete membrane staining in >10% of tumor cells | 3+ | | HER2+ = IHC3+ by DAKO scoring pre-ASCO/CAP
Yang et al. 2003 rec. # 8840 | | | | | 2+ | | HER2+ = IHC3+ by DAKO scoring pre-ASCO/CAP
Yang et al. 2003 rec. # 8840 | | | | | 1+ | | HER2+ = IHC3+ by DAKO scoring pre-ASCO/CAP
| | | | 0
Gusterson et al. 2003; rec. # 43690 | FISH | not done | FISH | not done | Pos
Gusterson et al. 2003; rec. # 43690 | IHC | ICR12 monoclonal antibody | | | Equiv
Gusterson et al. 2003; rec. # 43690 | | | | | Neg
Gusterson et al. 2003; rec. # 43690 | | | IHC | strong & complete membrane staining at dilution shown to give + signal if ≥3 copies of HER2 gene | Pos | | 16% of 760 node- pts; 19% of 746 node+ pts
Gusterson et al. 2003; rec. # 43690 | | | | | Equiv | | none
| | | | Neg | | 84% of 760 node- pts; 81 % of 746 node+ pts
Moliterni et. al. 2003; rec. # 10210 RCT; CMF (Grp1) vs CMF→A (Grp 2) | FISH | not done | FISH | not done | Pos
Moliterni et. al. 2003; rec. # 10210 RCT; CMF (Grp1) vs CMF→A (Grp 2) | IHC | CB11 antibody | | | Equiv
Moliterni et. al. 2003; rec. # 10210 RCT; CMF (Grp1) vs CMF→A (Grp 2) | | | | | Neg
Moliterni et. al. 2003; rec. # 10210 RCT; CMF (Grp1) vs CMF→A (Grp 2) | | | IHC | strong membrane staining found equivalent to 3+ by HercepTest | Pos | Grp1: | 18.2%; | Grp 2: | 16.2%
Moliterni et. al. 2003; rec. # 10210 RCT; CMF (Grp1) vs CMF→A (Grp 2) | | | | | Neg | | 75.6% | | 73.3%
| | | | ND | | 6.2% | | 10.5%
Colozza et al. 2005; rec. # 3820 RCT; CMF (Grp 1) vs epirubicin (Grp 2); n=133 each tested for HER2 status | FISH | not done | FISH | not done
Colozza et al. 2005; rec. # 3820 RCT; CMF (Grp 1) vs epirubicin (Grp 2); n=133 each tested for HER2 status | IHC | CB11 antibody and HercepTest | IHC | ≥50% CB11+ | HER+ | Grp 1: | 28% | Grp2: | 41%
Colozza et al. 2005; rec. # 3820 RCT; CMF (Grp 1) vs epirubicin (Grp 2); n=133 each tested for HER2 status | | | | ≤50% CB11+ | HER- | | 41% | | 36%
Colozza et al. 2005; rec. # 3820 RCT; CMF (Grp 1) vs epirubicin (Grp 2); n=133 each tested for HER2 status | | | | CB11 negative | HER- | | 31% | | 23%
Colozza et al. 2005; rec. # 3820 RCT; CMF (Grp 1) vs epirubicin (Grp 2); n=133 each tested for HER2 status | | | | HercepTest using | 3+ | | 7% | | 9%
Colozza et al. 2005; rec. # 3820 RCT; CMF (Grp 1) vs epirubicin (Grp 2); n=133 each tested for HER2 status | | | | DAKO scoring system | 2+ | | 7% | | 9%
Colozza et al. 2005; rec. # 3820 RCT; CMF (Grp 1) vs epirubicin (Grp 2); n=133 each tested for HER2 status | | | | | 1+ | | 10% | | 11%
| | | | 0 | | 75% | | 71%
Pritchard et al. 2006; rec. #1760 RCT; CMF versus CEF; | FISH | PathVysion kit | FISH | HER2/CEP17 ≥2.00 | Pos | 163 (26%) | also reported concordance rates between the different assays used
Pritchard et al. 2006; rec. #1760 RCT; CMF versus CEF; | IHC | CB11 and TAB 250 antibodies (results reported separately from each antibody assay) | | | Neg | 465 (74%) | also reported concordance rates between the different assays used
Pritchard et al. 2006; rec. #1760 RCT; CMF versus CEF; | PCR | as described by O'Malley et al. 2001; rec. #13790) | IHC | complete membrane staining, score ≥5 on Allred semi-quantitative scale | CB11+ | 124 (20%
Pritchard et al. 2006; rec. #1760 RCT; CMF versus CEF; | | | | | CB11- | 510 (80%) | PCR+ 195 (31%)
Pritchard et al. 2006; rec. #1760 RCT; CMF versus CEF; | | | | | TAB250+ | 116 (18%) | PCR- 429 (69%)
| | | | TAB250- | 516 (82%)
Knoop et al. 2005; rec. # 3450 RCT (n=805 tested) | FISH | pharmDx | FISH | HER2/CEP17 ≥2, as in kit manufacturer's manual; only tested if IHC2^+^ or 3^+^ followed instructions in manual for HercepTest kit | Pos | IHC2+: 21.0 | IHC3+: 89.4
Knoop et al. 2005; rec. # 3450 RCT (n=805 tested) | IHC | HercepTest | | HER2/CEP17 ≥2, as in kit manufacturer's manual; only tested if IHC2^+^ or 3^+^ followed instructions in manual for HercepTest kit | Equiv | 6.2 | 8.9
Knoop et al. 2005; rec. # 3450 RCT (n=805 tested) | | | | HER2/CEP17 ≥2, as in kit manufacturer's manual; only tested if IHC2^+^ or 3^+^ followed instructions in manual for HercepTest kit | Neg | 72.8 | 1.6
Knoop et al. 2005; rec. # 3450 RCT (n=805 tested) | | | IHC | HER2/CEP17 ≥2, as in kit manufacturer's manual; only tested if IHC2^+^ or 3^+^ followed instructions in manual for HercepTest kit | 3+ | 30.6
Knoop et al. 2005; rec. # 3450 RCT (n=805 tested) | | | | HER2/CEP17 ≥2, as in kit manufacturer's manual; only tested if IHC2^+^ or 3^+^ followed instructions in manual for HercepTest kit | 2+ | 10.1 | (IHC3+ or FISH+) = HER2+: 32.7%
Knoop et al. 2005; rec. # 3450 RCT (n=805 tested) | | | | HER2/CEP17 ≥2, as in kit manufacturer's manual; only tested if IHC2^+^ or 3^+^ followed instructions in manual for HercepTest kit | 1+ | 32.7 | HER2-: 67.3%
| | | 0 | 26.7
Dressler et al. 2005, rec. # 4280; Thor et al. 1998, rec. # 40880 | FISH | PathVysion kit | | | RCT arm: | [underlined: hiqh-dose] | [underlined: mod-dose] | [underlined: low-dose] | [underlined: total]
Dressler et al. 2005, rec. # 4280; Thor et al. 1998, rec. # 40880 | IHC | CB11 (n=346) or A0-11-854 (n=177) antibodies | FISH | HER2/CEP17 >2 | Pos | 30 (5.7%) | 31 (5.9%) | 30 (5.7%) | 91 (17%)
Dressler et al. 2005, rec. # 4280; Thor et al. 1998, rec. # 40880 | | | | | Neg | 149 (28.4%) | 136 (26.0%) | 148 (28.2%) | 433 (83%)
Dressler et al. 2005, rec. # 4280; Thor et al. 1998, rec. # 40880 | PCR | differential PCR assay as described in Thor et al. 1998 | IHC | ≥50% of invasive cells stained by antibody | Pos | 44 (8.4%) | 43 (8.2%) | 40 (7.7%) | 127 (24%)
Dressler et al. 2005, rec. # 4280; Thor et al. 1998, rec. # 40880 | | | | | Neg | 134 (25.6%) | 124 (23.7%) | 138 (26.4%) | 396 (76%)
Dressler et al. 2005, rec. # 4280; Thor et al. 1998, rec. # 40880 | | | PCR | “unequivocal amplification relative to ...normal...and amplified standard controls” | Pos | 30 (6.1%) | 31 (6.3%) | 30 (6.1%) | 91 (18%)
| | | | Neg | 131 (26.7%) | 125 (25.5%) | 144 (29.3%) | 400 (82%)
Del Mastro et al. 2004, 2005; rec. # 48020 | FISH | not done | FISH | not done | Pos
Del Mastro et al. 2004, 2005; rec. # 48020 | IHC | CB11 antibody | | | Neg
Del Mastro et al. 2004, 2005; rec. # 48020 | | | | | | FEC_14_ (n=370) | FEC_21_ (n=361)
Del Mastro et al. 2004, 2005; rec. # 48020 | | all slides scored by one pathologist, blinded to treatment arm & outcome | IHC | 3+ score on Dako scale: 103 of 731 (14%) with specimens available for assay | 3+ | 50 (13.5%) | 53 (14.7%)
Del Mastro et al. 2004, 2005; rec. # 48020 | | | | | 2+ | 24 (6.5%) | 23 (6.4%)
Del Mastro et al. 2004, 2005; rec. # 48020 | | | | | 1+ | 19 (5.1%) | 20 (5.5%)
| | | | 0 | 277 (74.9%) | 265 (73.4%)
Tanner et al. 2006; rec. # 1820 data for n=180 from FEC arm tested for HER2 status | FISH | not done | CISH | ≥6 copies in >30% of invasive carcinoma cells or ratio >2, HER2/CEP17 | Pos | 56 (31%)
Tanner et al. 2006; rec. # 1820 data for n=180 from FEC arm tested for HER2 status | CISH | Zymed probes (digoxigenin-labeled) | | | Equiv | 0
Tanner et al. 2006; rec. # 1820 data for n=180 from FEC arm tested for HER2 status | IHC | not done | | | Neg | 124 (69%)
Tanner et al. 2006; rec. # 1820 data for n=180 from FEC arm tested for HER2 status | | | IHC | | 3+
Tanner et al. 2006; rec. # 1820 data for n=180 from FEC arm tested for HER2 status | | | | | 2+
Tanner et al. 2006; rec. # 1820 data for n=180 from FEC arm tested for HER2 status | | | | | 1+
| | | | 0
Hayes et al. 2007; rec. # 47610 | FISH | PathVysion kit | FISH | HER2/CEP17 ≥2.00 | Pos | proportions of HER2+ and HER2- patients not reported for any assay method
Hayes et al. 2007; rec. # 47610 | IHC | CB11 antibody and HercepTest | | | Equiv | proportions of HER2+ and HER2- patients not reported for any assay method
Hayes et al. 2007; rec. # 47610 | | | | | Neg | proportions of HER2+ and HER2- patients not reported for any assay method
Hayes et al. 2007; rec. # 47610 | | | IHC | CB11: HER2+if ≥50% of breast cancer cells were stained; Herceptest: as in Dako manual | 3+ | proportions of HER2+ and HER2- patients not reported for any assay method
Hayes et al. 2007; rec. # 47610 | | | | | 2+ | proportions of HER2+ and HER2- patients not reported for any assay method
Hayes et al. 2007; rec. # 47610 | | | | | 1+ | proportions of HER2+ and HER2- patients not reported for any assay method
| | | | 0
Martin et al. 2005; rec # 47650 | FISH | not reported | FISH | HER2/CEP17 ≥2.00 | Pos | 319 (21.4%; 20.8%, DAC arm; 22.0% FAC arm)
Martin et al. 2005; rec # 47650 | IHC | CB11 antibody (only for 12 patients) | | | Neg | 943 (63.3%; 63.8%, DAC arm; 62.7% FAC arm)
Martin et al. 2005; rec # 47650 | | | | | ??? | 229 (15.4%; 15.4%, DAC arm; 15.3% FAC arm)
| | IHC | not reported
Neoadjuvant (Pre-operative) Chemotherapy
Learn et al. 2005; rec. # 47640 n=104 classified for HER2 status | FISH | not reported | FISH | not reported
Learn et al. 2005; rec. # 47640 n=104 classified for HER2 status | IHC | TAB250 antibody (Zymed; South San Francisco, CA) | | | HER2 Pos | 41 (39.4% of those tested)
| FISH performed on all specimens with “borderline” HER2 IHC scores | IHC | not reported | HER2 Neg | 63 (60.6% of those tested)
Arriola et al. 2006; rec # 950 n=223 tested by IHC/FISH initial algorithm & by CISH | FISH | Oncor/Ventana Inform kit | CISH | >5 copies or ratio>2 for | | >5 copies | ratio>2
Arriola et al. 2006; rec # 950 n=223 tested by IHC/FISH initial algorithm & by CISH | CISH | Zymed probe and Spot-Light kit | | HER2/CEN17 | Pos | 18% | 14%
Arriola et al. 2006; rec # 950 n=223 tested by IHC/FISH initial algorithm & by CISH | IHC | CB11 antibody and HercepTest | | | Neg | 82% | 86%
Arriola et al. 2006; rec # 950 n=223 tested by IHC/FISH initial algorithm & by CISH | algorithm: CB11 first, then HercepTest for negatives only, then FISH for discordant IHC results; positives by initial algorithm tested byCISH | | IHC/FISH initial algorithm: CB11^+^ if complete membrane staining in >10% of cells; HercepTest^+^ if 2^+^ or 3+; FISH^+^ if >4 signals/cell | | Pos | 19%
| | | | Neg | 81%
Park et al. 2003; rec # 9960 | FISH | not done | FISH | not done
Park et al. 2003; rec # 9960 | CISH | Zymed SPOT-Light HER2 probe, digoxigenin-labeled | CISH | HER2 gene copy # >4, or large gene copy cluster in >50% of cancer cell nude | Pos | 46%
Park et al. 2003; rec # 9960 | | | | | Neg | 54%
IHC | not done | IHC | not done
Zhang et al. 2003; rec # 9820 | FISH | PathVysion kit | FISH | gene copy ratio >2.0, HER2/chromosome 17 centromere | Pos | 13% | overall, 28% (n=28) HER2^+^ defined as 3+ by IHC or FISH+; 72% (n=69) HER2-
Zhang et al. 2003; rec # 9820 | IHC | AB8 Neomarker antibody | | | Neg | 36% | overall, 28% (n=28) HER2^+^ defined as 3+ by IHC or FISH+; 72% (n=69) HER2-
Zhang et al. 2003; rec # 9820 | | | | | untested | 51% | overall, 28% (n=28) HER2^+^ defined as 3+ by IHC or FISH+; 72% (n=69) HER2-
Zhang et al. 2003; rec # 9820 | n=75 analyzed by IHC | | IHC | strong membrane staining in ≥10% of tumor cells | 3+ | 23% | overall, 28% (n=28) HER2^+^ defined as 3+ by IHC or FISH+; 72% (n=69) HER2-
Zhang et al. 2003; rec # 9820 | n=48 analyzed by FISH | | | | 2+ | 9% | overall, 28% (n=28) HER2^+^ defined as 3+ by IHC or FISH+; 72% (n=69) HER2-
Zhang et al. 2003; rec # 9820 | n=97 all patients in study | | | | 1+ | 10% | overall, 28% (n=28) HER2^+^ defined as 3+ by IHC or FISH+; 72% (n=69) HER2-
Zhang et al. 2003; rec # 9820 | | | | | 0 | 35% | overall, 28% (n=28) HER2^+^ defined as 3+ by IHC or FISH+; 72% (n=69) HER2-
| | | | untested | 23%
Tulbah et al. 2002; rec # 11560 n=54 tested | FISH | not done | FISH | not done | Pos
Tulbah et al. 2002; rec # 11560 n=54 tested | IHC | HercepTest | | | Equiv
Tulbah et al. 2002; rec # 11560 n=54 tested | | | | | Neg
Tulbah et al. 2002; rec # 11560 n=54 tested | | | IHC | scored 0–3+, as in Dako kit guide; for analysis of response, only 3+ was considered HER2+ | 3+ | 22 (41%)
Tulbah et al. 2002; rec # 11560 n=54 tested | | | | | 2+ | 12 (22%)
Tulbah et al. 2002; rec # 11560 n=54 tested | | | | | 1+ | 8 (15%)
| | | | 0 | 12 (22%)
Tinari et al. 2006; rec # 2300 retrospective single-arm series; n=77 | FISH | not reported | FISH | not reported; used only if HercepTest scored 2+ | Pos | 20 (26%)
Tinari et al. 2006; rec # 2300 retrospective single-arm series; n=77 | IHC | HercepTest (Dako) | | | Equiv | 0
Tinari et al. 2006; rec # 2300 retrospective single-arm series; n=77 | | | | | Neg | 57 (74%)
Tinari et al. 2006; rec # 2300 retrospective single-arm series; n=77 | | | IHC | scored 0–3+, as in Dako kit guide; positive if IHC scored 3+ or if FISH+ and IHC 2+ | 3+
Tinari et al. 2006; rec # 2300 retrospective single-arm series; n=77 | | | | | 2+
Tinari et al. 2006; rec # 2300 retrospective single-arm series; n=77 | | | | | 1+
| | | | 0
Chemotherapy for Advanced or Metastatic Disease
Harris et al 2006; rec. # 390 | FISH | Vysis PathVysion kit (Vysis Inc, Downers Grove, IL) | FISH | Ratio of HER2 to CEP17 signal ≥ 2.0. | Pos | 26 | | Cohen's kappa = 83.0% (SE5.3%) for FISH vs CB11; 72.0%(SE6.2%) for Hercep-Test (0–1 vs 2–3) vs FISH; 79.2%(SE6.0%) for Hercep-Test (0–2 vs 3) vs FISH; 70.0%(SE6.3%) for Hercep-Test (0–1 vs2–3) vs CB11; 84.2%(SE5.4%) for Hercep-Test (1–2 vs 3) vs CB11.
Harris et al 2006; rec. # 390 | | | | | Neg | 74
Harris et al 2006; rec. # 390 | IHC | Monoclonol antibody CB11 (Biogenex, San Ramon, CA); HercepTest (Dako Corp, Carpinteria, CA) | IHC | CB11 : moderate to strong intensity staining in ≥10% of invasive carcinoma cells.
Harris et al 2006; rec. # 390 | | | | | Pos | 20
Harris et al 2006; rec. # 390 | | | | | Equiv
Harris et al 2006; rec. # 390 | | | | | Neg | 80
Harris et al 2006; rec. # 390 | | | | Herceptest score of 3+; i.e., complete membrane staining of >10% tumor cells | 0 | 40
Harris et al 2006; rec. # 390 | | | | | 1 | 28 | | By CB11, 9% of African American women are HER2+ vs 20% of Caucasian women (p=0.08).
Harris et al 2006; rec. # 390 | | | | | 2 | 11
| | | | 3 | 21
Di Leo et al 2004; rec. # 5970 | IHC | CB-11 (Novocastra, Newcastle, UK) | | | | Grp1 | Grp2
Di Leo et al 2004; rec. # 5970 | | | IHC → | FISH: FISH done if IHC stained membranes in ≥ 1% of invasive cells; HER2+ if signal ratio, HER2/CEP17 ≥2 | Pos | 16% | 25%
Di Leo et al 2004; rec. # 5970 | FISH | Spectrum Orange HER-2/Spectrum Green CEP17 (PathVysion, Vysis, Downers Grove, IL) | | | unknown | 14% | 16%
| | | | Neg | 69% | 59%
Konecny et al 2004; rec. # 6740 | FISH | PathVision HER-2 Neu & CEP17 probes (Vysis, Downers Grove, IL) | | | | Grp1 | Grp2
Konecny et al 2004; rec. # 6740 | | | FISH | ≥2 HER-2/neu genes per Chromosome 17 Centromere | Pos | 35.8 | 34.8
Konecny et al 2004; rec. # 6740 | | | | | Equiv
Konecny et al 2004; rec. # 6740 | | | | | Neg | 64.2 | 65.2
IHC | not done

Table IIIa-D Outcome Assessment

Study | Primary Outcomes | Secondary Outcomes | Criteria for Tumor Response or Progression | Independent Response Assessor? | F/U Frequency/Duration
Adjuvant Chemotherapy
Yang et al. 2003 rec. # 8840 | DFS | no others reported by HER2 status | not specified | not mentioned | not reported
Gusterson et al. 2003; rec. # 43690 | DFS, OS | no others reported by HER2 status | not specified | not mentioned | 6 yrs median F/U duration frequency not reported
Moliterni et. al. 2003; rec. # 10210 | RFS, OS | no others reported by HER2 status | relapse: any new manifestation of disease (locoregional, distant or contralateral) | not mentioned | q3wk during Tx (1 yr), then q6mo for 5 yr, then q12 mo; median F/U duration, 178 mo
Colozza et al. 2005; rec. # 3820 | RFS, OS | no others reported by HER2 status | relapse: any new manifestation of disease (locoregional, distant or contralateral) | not mentioned | 8 years median F/U duration (range, 6.4–9.5 years); frequency not reported
Pritchard et al. 2006; rec. # 1760 | RFS, OS | no others reported by HER2 status | recurrence: local, chest wall, regional or distant disease; but contralateral = new primary | not mentioned | q3mo to end of year 2, then q6mo to end of year 5, then yearly; median F/U 10 yrs; minimum F/U 9 years
Knoop et al. 2005; rec. # 3450 | RFS, OS | no others reported by HER2 status | recurrence: local, regional, distant, 2^nd^ malignancy or death | not mentioned | median estimated potential F/U: 8 yr for RFS, 10 yr for OS; F/U frequency not reported
Dressler et al. 2005, rec. # 4280; Thor et al. 1998, rec. # 40880 | DFS, OS | no other outcomes reported by HER2 status | for DFS, event = documented relapse or death; progression not defined | not mentioned | F/U frequency not reported; median F/U duration, 9 years
Del Mastro et al. 2004, 2005; rec. # 48020 | EFS, OS | no others reported | for EFS, event = local or distant relapse, 2^nd^ breast primary, or death | not mentioned for events, but HER2 scoring blinded | frequency not reported; median F/U duration, 6.7 years
Tanner et al. 2006; rec. # 1820 | RFS, OS | no others reported by HER2 status | RFS: breast cancer specific survival from randomization to first recurrence | not mentioned (but CISH analyses blinded to outcome) | not reported (but may be in original report, ref. 16)
Hayes et al. 2007; rec# 47610 | DFS | OS; no others by HER2 status | event = first local or distant recurrence or death | not mentioned | F/U frequency not reported; F/U duration “approximately 10 years”
Martin et al. 2005; rec # 47650 | DFS | OS, adverse events, QOL; none reported by HER2 status | not specified | not mentioned | day 21 of each cycle, then every 6 mos for 5 years, then annually; median F/U 55 months
Neoadjuvant (Pre-operative) Chemotherapy
Learn et al. 2005; rec. # 47640 | pathologic and clinical responses | no other outcomes reported | pCR: no residual invasive cells in resected tumor or nodes; cCR: 100% tumor regression; cPR: 50–99% tumor regression; ORR: cCR + cPR no response (cNR): <50% regression and <25% growth progressive disease (PD): (25% tumor growth | not mentioned for either response or HER2 assays | clinical responses evaluated after 12 weeks of chemotherapy but before surgery; pathologic response determined on resected tumor and nodes
Arriola et al. 2006; rec # 950 | pathologic complete response (pCR) | clinical response; other outcomes not reported | pCR: no invasive tumor cells; clinical response: >50% ↓, product of maximal diameters; progression: 25% ↑, product of maximal diameters; | not relevant? | physical exam q3wk during neoadj Tx; repeat mammography ≥15 days post 4^th^ cycle of doxorubicin to assess clinical response; pathologic response assessed after surgery
Park et al. 2003; rec # 9960 | clinical & pathologic responses | other outcomes not reported | pCR: no invasive cancer; cCR: not defined PR: >50% ↓ tumor volume; SD: <50% ↓ tumor volume | not relevant? | physical exam q1wk during neoadj Tx; repeat MRI before surgery after completion of 4 chemoTx cycles
Zhang et al. 2003; rec # 9820 | pathologic, clinical, & imaging responses (imaging responses by mammography, ultrasonography, or both) | DFS; other outcomes not reported | pCR: no invasive tumor in resected breast tissue or nodes MRD: <1 cm diam in breast & no positive nodes ERD: >1 cm diam in breast or any positive node cCR: no evidence of tumor in breast or lymph nodes; cPR: >50%↓ in tumor size cSD: <50%↓ to <25% ↑ in tumor size; cPD: >25% ↑ in tumor size | not relevant? path. good responses = pCR + MRD; clin. good responses = cCR + cPR | physical exam at baseline & at start of each neoadjuvant chemoTx cycle to assess clinical responses; imaging at baseline & between end of final chemoTx cycle & surgery to assess imaging responses; pathologic responses assessed by microscopic evaluation of resected breast tissue and nodes; n=61 (63%) had mastectomy, 36 (37%) had breast conserving surgery; median F/U for DFS: 33 months
Tulbah et al. 2002; rec # 11560 | pathologic and clinical responses | DFS, OS; other outcomes not reported | pCR, pPR, pSD, pPD as described by Feldman et al (ref. 27); cCR, cPR, cSD, cPD as previously described (ref. 19); events for DFS: local, regional, or distant recurrence; contralateral breast cancer; any other primary cancer; or death | not mentioned for response or progression; HER2 assessor blinded to outcome | F/U frequency not described; median F/U duration, 25 (±7) months
Tinari et al. 2006; rec # 2300 | pathologic responses | reported RFS, but not by HER2 status | pCR: no invasive tumor in resected breast tissue or nodes MRD: no gross tumor, microscopic invasive tumor in ≤2 high-powered fields PR: >50% ↓ in all lesions SD: <25% Δ in size, each lesion PD: >25% ↑ in size, any lesion tumor response (TR): pCR or MRD overall response (OR): pCR, MRD or PR | not mentioned for response or progression; HER2 assessor blinded to outcome | physical exam, bilateral mammography, blood chemistry, CEA, CA 15-3, chest X-ray every 3 months for 2 years, every 6 months thereafter; bone scan every 6 months; pathologivc response to treatment assessed after tumor excision and axillary lymph node dissection (median of 10 nodes excised per patient)
Chemotherapy for Adavanced or Metastatic Disease
Harris et al 2006; rec. # 390 | Radiographic response | TTF, OS | Disappearance of all lesions (CR) or ≥ 50% reduction in sum of the products of bidimensional measurements of all lesions, with improvement or no change in any nonmeasurable lesions (PR) | Not reported | “Std staging studies” after every 3 cycles; median follow-up=8.3 years
Di Leo et al 2004; rec. # 5970 | TTP | OS; clinical/imaging response | WHO criteria; ORR=%CR+%PR | Not reported | Before, during, and every 3 mos after treatment, to progression or death. Median FU=23 months.
Konecny et al 2004; rec. # 6740 | did not specify primary outcome; reported clinical/imaging response rates, PFS, OS (each from randomization) | | CR=disappearance of all radiographically or visually apparent tumor; PR=>50% decrease (2D measurements) of all measurable lesions; ORR=%CR+%PR; Progression= >25% increase in any measurable lesion or appearance of new lesion | Not routinely | FU every 12 weeks; F/U duration not reported

Table IIIa-E Time to Event Outcomes

Study | Time to Event Outcomes
Adjuvant Chemotherapy
Yang et al. 2003 rec. # 8840 CMF; single-arm series | Outcome | Grp | N | Med (mos) | 1 yr | 2.5 yr | 3 yr | 4 yr | 5 yr | | Test | p | HR (95%CI) | Comments
Yang et al. 2003 rec. # 8840 CMF; single-arm series | OS | HER2+
Yang et al. 2003 rec. # 8840 CMF; single-arm series | | HER2-
Yang et al. 2003 rec. # 8840 CMF; single-arm series | TTP | HER2+
Yang et al. 2003 rec. # 8840 CMF; single-arm series | | HER2-
Yang et al. 2003 rec. # 8840 CMF; single-arm series | PFS | HER2+
Yang et al. 2003 rec. # 8840 CMF; single-arm series | | HER2-
Yang et al. 2003 rec. # 8840 CMF; single-arm series | RFS | HER2+
Yang et al. 2003 rec. # 8840 CMF; single-arm series | | HER2- | | | | | | | | | | | | also reported stratified log rank that adjusted for nodal status (p=0.002)
Yang et al. 2003 rec. # 8840 CMF; single-arm series | DFS | HER2+ | 34 | 6–7 years | | ~60% | | | 53% | | log rank | <0.01 | | also reported stratified log rank that adjusted for nodal status (p=0.002)
| HER2- | 60 | not reached | | ~90% | | | 86%
Gusterson et al. 2003; rec. #43690 760 node- pts randomized to periop CMF (Tx) or no adj Tx (Cx) | Outcome | Grp | N | Med (mos) | 2 yr | 3 yr | 4 yr | 5 yr | 6 yr | | Test | p | HR (95%CI) | Comments
Gusterson et al. 2003; rec. #43690 760 node- pts randomized to periop CMF (Tx) or no adj Tx (Cx) | OS (HER2+) | Tx | 64 | not reached | | | | | 76±5 | | Cox | NS | 1.15 (0.54–2.46) | unadjusted univariate analyses; adjusted results also NS
Gusterson et al. 2003; rec. #43690 760 node- pts randomized to periop CMF (Tx) or no adj Tx (Cx) | | Cx | 54 | not reached | | | | | 79±6 | | prop hazards | | | unadjusted univariate analyses; adjusted results also NS
Gusterson et al. 2003; rec. #43690 760 node- pts randomized to periop CMF (Tx) or no adj Tx (Cx) | OS (HER2-) | Tx | 436 | not reached | | | | | 85±2 | | Cox | NS | 1.04 (0.68–1.61) | unadjusted univariate analyses; adjusted results also NS
Gusterson et al. 2003; rec. #43690 760 node- pts randomized to periop CMF (Tx) or no adj Tx (Cx) | | Cx | 206 | not reached | | | | | 87±2 | | prop hazards
Gusterson et al. 2003; rec. #43690 760 node- pts randomized to periop CMF (Tx) or no adj Tx (Cx) | TTP | Tx
Gusterson et al. 2003; rec. #43690 760 node- pts randomized to periop CMF (Tx) or no adj Tx (Cx) | | Cx
Gusterson et al. 2003; rec. #43690 760 node- pts randomized to periop CMF (Tx) or no adj Tx (Cx) | PFS | Tx
Gusterson et al. 2003; rec. #43690 760 node- pts randomized to periop CMF (Tx) or no adj Tx (Cx) | | Cx
Gusterson et al. 2003; rec. #43690 760 node- pts randomized to periop CMF (Tx) or no adj Tx (Cx) | RFS | Tx
Gusterson et al. 2003; rec. #43690 760 node- pts randomized to periop CMF (Tx) or no adj Tx (Cx) | | Cx
Gusterson et al. 2003; rec. #43690 760 node- pts randomized to periop CMF (Tx) or no adj Tx (Cx) | DFS(HER2+) | Tx | 64 | not reached | ~84% | ~68% | ~65% | ~62% | 61±6 | | Cox | NS | 1.22 (0.66–2.25) | unadjusted univariate analyses; adjusted results also NS
Gusterson et al. 2003; rec. #43690 760 node- pts randomized to periop CMF (Tx) or no adj Tx (Cx) | | Cx | 54 | not reached | ~86% | ~75% | ~73% | ~70% | 68±7 | | prop hazards | | | unadjusted univariate analyses; adjusted results also NS
Gusterson et al. 2003; rec. #43690 760 node- pts randomized to periop CMF (Tx) or no adj Tx (Cx) | DFS (HER2-) | Tx | 436 | not reached | ~90% | ~85% | ~80% | ~77% | 71±2 | | Cox | NS | 0.82 (0.61–1.09) | unadjusted univariate analyses; adjusted results also NS
| Cx | 206 | not reached | ~85% | ~77% | ~72% | ~70% | 68±3 | | prop hazards
Gusterson et al. 2003; rec. #43690 746 node+ pts randomized to periop (Cx) or prolonged (Tx) CMF | Outcome | Grp | N | Med (mos) | 2 yr | 3 yr | 4 yr | 5 yr | 6 yr | | Test | p | HR (95%CI) | Comments
Gusterson et al. 2003; rec. #43690 746 node+ pts randomized to periop (Cx) or prolonged (Tx) CMF | OS (HER2+) | Tx | 85 | not reported | | | | | 46±6 | | Cox | NS | 1.15 (0.62–1.54) | unadjusted univariate analyses; adjusted analyses gave similar results
Gusterson et al. 2003; rec. #43690 746 node+ pts randomized to periop (Cx) or prolonged (Tx) CMF | | Cx | 55 | not reported | | | | | 40±7 | | prop hazards | | | unadjusted univariate analyses; adjusted analyses gave similar results
Gusterson et al. 2003; rec. #43690 746 node+ pts randomized to periop (Cx) or prolonged (Tx) CMF | OS (HER2-) | Tx | 406 | not reached | | | | | 71±2 | | Cox | 0.01 | 0.69 (0.52–0.92) | unadjusted univariate analyses; adjusted analyses gave similar results
Gusterson et al. 2003; rec. #43690 746 node+ pts randomized to periop (Cx) or prolonged (Tx) CMF | | Cx | 200 | not reached | | | | | 61±4 | | prop hazards
Gusterson et al. 2003; rec. #43690 746 node+ pts randomized to periop (Cx) or prolonged (Tx) CMF | TTP | Tx
Gusterson et al. 2003; rec. #43690 746 node+ pts randomized to periop (Cx) or prolonged (Tx) CMF | | Cx
Gusterson et al. 2003; rec. #43690 746 node+ pts randomized to periop (Cx) or prolonged (Tx) CMF | PFS | Tx
Gusterson et al. 2003; rec. #43690 746 node+ pts randomized to periop (Cx) or prolonged (Tx) CMF | | Cx
Gusterson et al. 2003; rec. #43690 746 node+ pts randomized to periop (Cx) or prolonged (Tx) CMF | RFS | Tx
Gusterson et al. 2003; rec. #43690 746 node+ pts randomized to periop (Cx) or prolonged (Tx) CMF | | Cx
Gusterson et al. 2003; rec. #43690 746 node+ pts randomized to periop (Cx) or prolonged (Tx) CMF | DFS(HER2+) | Tx | 85 | ~36 | ~60% | ~50% | ~43% | ~40% | 38±5 | | Cox | NS | 0.77 (0.51–1.16) | unadjusted univariate analyses; adjusted analyses gave similar results
Gusterson et al. 2003; rec. #43690 746 node+ pts randomized to periop (Cx) or prolonged (Tx) CMF | | Cx | 55 | ~24 | ~50% | ~42% | ~35% | ~30% | 29±6 | | prop hazards | | | unadjusted univariate analyses; adjusted analyses gave similar results
Gusterson et al. 2003; rec. #43690 746 node+ pts randomized to periop (Cx) or prolonged (Tx) CMF | DFS (HER2-) | Tx | 406 | >72 | ~80% | ~70% | ~63% | ~57% | 52±3 | | Cox | <0.0001 | 0.57 (0.46–0.72) | unadjusted univariate analyses; adjusted analyses gave similar results
| Cx | 200 | ~40 | ~63% | ~55% | ~45% | ~40% | 36±4 | | prop hazards
Moliterni et. al. 2003; rec. #10210 RCT; CMF (Cx) versus CMF→A (Tx) | Outcome | Grp | N | Med (mos) | 2 yr | 4 yr | 6 yr | 8 yr | 10 yr | | Test | p | HR (95%CI) | Comments
Moliterni et. al. 2003; rec. #10210 RCT; CMF (Cx) versus CMF→A (Tx) | OS (HER2+) | Tx | 45 | >192 | ~92% | ~83% | ~73% | ~68% | 64% | | Cox | | 0.61 (0.32–1.16) | Comments
Moliterni et. al. 2003; rec. #10210 RCT; CMF (Cx) versus CMF→A (Tx) | | Cx | 50 | ~170 | ~90% | ~80% | ~63% | ~57% | 54% | | model | | | Comments
Moliterni et. al. 2003; rec. #10210 RCT; CMF (Cx) versus CMF→A (Tx) | OS (HER2-) | Tx | 203 | >192 | ~97% | ~90% | ~86% | ~83% | 76% | | Cox | | 1.26 (0.89–1.79) | Comments
Moliterni et. al. 2003; rec. #10210 RCT; CMF (Cx) versus CMF→A (Tx) | | Cx | 208 | >192 | ~97% | ~94% | ~90% | ~83% | 77% | | model | | | Comments
Moliterni et. al. 2003; rec. #10210 RCT; CMF (Cx) versus CMF→A (Tx) | TTP | Tx | | | | | | | | | | | | Comments
Moliterni et. al. 2003; rec. #10210 RCT; CMF (Cx) versus CMF→A (Tx) | | Cx | | | | | | | | | | | | Comments
Moliterni et. al. 2003; rec. #10210 RCT; CMF (Cx) versus CMF→A (Tx) | PFS | Tx | | | | | | | | | | | | Comments
Moliterni et. al. 2003; rec. #10210 RCT; CMF (Cx) versus CMF→A (Tx) | | Cx | | | | | | | | | | | | Comments
Moliterni et. al. 2003; rec. #10210 RCT; CMF (Cx) versus CMF→A (Tx) | RFS(HER2+) | Tx | 45 | >192 | ~85% | ~75% | ~62% | ~58% | 55% | | Cox | | 0.83 (0.46–1.49) | Comments
Moliterni et. al. 2003; rec. #10210 RCT; CMF (Cx) versus CMF→A (Tx) | | Cx | 50 | ~102 | ~85% | ~65% | ~62% | ~52% | 46% | | model | | | Comments
Moliterni et. al. 2003; rec. #10210 RCT; CMF (Cx) versus CMF→A (Tx) | RFS (HER2-) | Tx | 203 | ~162 | ~90% | ~80% | ~65% | ~60% | 56% | | Cox | | 1.22 (0.91–1.64) | Comments
Moliterni et. al. 2003; rec. #10210 RCT; CMF (Cx) versus CMF→A (Tx) | | Cx | 208 | >192 | ~90% | ~80% | ~74% | ~65% | 59% | | model | | | Comments
Moliterni et. al. 2003; rec. #10210 RCT; CMF (Cx) versus CMF→A (Tx) | DFS | Tx | | | | | | | | | | | | Comments
| Cx
Colozza et al. 2005; rec. # 3820 RCT; CMF (Cx) vs epirubicin (Tx); n=133 each group tested for HER2 status | Outcome | Grp | N | Med (mos) | | 4 yr | 6 yr | % at 8 yr±SD | | | Test | p | HR (95%CI) | Comments: data at 8 yrs from Table 4; n per HER2+ group disagrees with Tables 1 & 2 CMF HER2+ versus CMF HER2- p=0.024 all other comparisons not significant, including epirubicin HER2+ versus epirubicin HER2- p=0.24
Colozza et al. 2005; rec. # 3820 RCT; CMF (Cx) vs epirubicin (Tx); n=133 each group tested for HER2 status | OS (HER2+) | Tx | 54 | not reached | | ~89% | ~80% | 75.8±5.8 | | | log
Colozza et al. 2005; rec. # 3820 RCT; CMF (Cx) vs epirubicin (Tx); n=133 each group tested for HER2 status | | Cx | 37 | not reached | | ~77% | ~70% | 67.6±7.7 | | | rank
Colozza et al. 2005; rec. # 3820 RCT; CMF (Cx) vs epirubicin (Tx); n=133 each group tested for HER2 status | OS (HER2-) | Tx | 79 | not reached | | ~90% | ~87% | 84.5±4.1 | | | log
Colozza et al. 2005; rec. # 3820 RCT; CMF (Cx) vs epirubicin (Tx); n=133 each group tested for HER2 status | | Cx | 96 | not reached | | ~93% | ~90% | 87.4±3.4 | | | rank
Colozza et al. 2005; rec. # 3820 RCT; CMF (Cx) vs epirubicin (Tx); n=133 each group tested for HER2 status | TTP | Tx
Colozza et al. 2005; rec. # 3820 RCT; CMF (Cx) vs epirubicin (Tx); n=133 each group tested for HER2 status | | Cx
Colozza et al. 2005; rec. # 3820 RCT; CMF (Cx) vs epirubicin (Tx); n=133 each group tested for HER2 status | PFS | Tx
Colozza et al. 2005; rec. # 3820 RCT; CMF (Cx) vs epirubicin (Tx); n=133 each group tested for HER2 status | | Cx
Colozza et al. 2005; rec. # 3820 RCT; CMF (Cx) vs epirubicin (Tx); n=133 each group tested for HER2 status | RFS(HER2+) | Tx | 54 | | | | | 60.1±6.9 | | | log
Colozza et al. 2005; rec. # 3820 RCT; CMF (Cx) vs epirubicin (Tx); n=133 each group tested for HER2 status | | Cx | 37 | | | | | 68.6±7.2 | | | rank
Colozza et al. 2005; rec. # 3820 RCT; CMF (Cx) vs epirubicin (Tx); n=133 each group tested for HER2 status | RFS (HER2-) | Tx | 79 | | | | | 65.9±5.4 | | | log
Colozza et al. 2005; rec. # 3820 RCT; CMF (Cx) vs epirubicin (Tx); n=133 each group tested for HER2 status | | Cx | 96 | | | | | 70.3±4.7 | | | rank
Colozza et al. 2005; rec. # 3820 RCT; CMF (Cx) vs epirubicin (Tx); n=133 each group tested for HER2 status | DFS | Tx
| Cx
Pritchard et al. 2006; rec. # 1760 RCT; CMF (Cx) versus CEF (Tx); HER2 status by FISH results | Outcome | Grp | N | Med (yrs) | 2 yr | 4 yr | 6 yr | 8 yr | 10 yr | | Test | p | HR (95%CI) | Comments
Pritchard et al. 2006; rec. # 1760 RCT; CMF (Cx) versus CEF (Tx); HER2 status by FISH results | OS (HER2^+^) | Tx | 75 | not reached | ~93% | ~70% | ~62% | ~58% | ~57% | | log | 0.06 | 0.65 (0.42–1.02) | Comments
Pritchard et al. 2006; rec. # 1760 RCT; CMF (Cx) versus CEF (Tx); HER2 status by FISH results | | Cx | 88 | ~5.3 | ~92% | ~62% | ~47% | ~46% | ~45% | | rank | | | Comments
Pritchard et al. 2006; rec. # 1760 RCT; CMF (Cx) versus CEF (Tx); HER2 status by FISH results | OS (HER2^-^) | Tx | 237 | not reached | ~93% | ~83% | ~75% | ~67% | ~63% | | log | NS | 1.06 (0.83–1.44) | Comments
Pritchard et al. 2006; rec. # 1760 RCT; CMF (Cx) versus CEF (Tx); HER2 status by FISH results | | Cx | 228 | not reached | ~93% | ~80% | ~75% | ~67% | ~62% | | rank | | | Comments
Pritchard et al. 2006; rec. # 1760 RCT; CMF (Cx) versus CEF (Tx); HER2 status by FISH results | TTP | Tx | | | | | | | | | | | | Comments
Pritchard et al. 2006; rec. # 1760 RCT; CMF (Cx) versus CEF (Tx); HER2 status by FISH results | | Cx | | | | | | | | | | | | Comments
Pritchard et al. 2006; rec. # 1760 RCT; CMF (Cx) versus CEF (Tx); HER2 status by FISH results | PFS | Tx | | | | | | | | | | | | Comments
Pritchard et al. 2006; rec. # 1760 RCT; CMF (Cx) versus CEF (Tx); HER2 status by FISH results | | Cx | | | | | | | | | | | | Comments
Pritchard et al. 2006; rec. # 1760 RCT; CMF (Cx) versus CEF (Tx); HER2 status by FISH results | RFS (HER2^+^) | Tx | 75 | not reached | ~77% | ~67% | ~58% | ~57% | ~56% | | log | 0.003 | 0.52 (0.34–0.80) | Comments
Pritchard et al. 2006; rec. # 1760 RCT; CMF (Cx) versus CEF (Tx); HER2 status by FISH results | | Cx | 88 | ~2.5 | ~63% | ~43% | ~42% | ~34% | ~31% | | rank | | | Comments
Pritchard et al. 2006; rec. # 1760 RCT; CMF (Cx) versus CEF (Tx); HER2 status by FISH results | RFS (HER2^-^) | Tx | 237 | ~10 | ~81% | ~67% | ~60% | ~54% | ~50% | | log | NS | 0.91 (0.71–1.18) | Comments
| Cx | 228 | ~10 | ~81% | ~64% | ~58% | ~54% | ~50% | | rank
Knoop et al. 2005; rec. # 3450 RCT (n=805); CMF (Cx) versus CEF (Tx) | Outcome | Grp | N | Med (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | | Test | p | HR (95%CI) | Comments
Knoop et al. 2005; rec. # 3450 RCT (n=805); CMF (Cx) versus CEF (Tx) | OS (HER2+) | Tx | 120 | | | | | | | | Cox | 0.09 | 0.73 (0.50–1.05) | HR's and 95% CI's all adjusted by multivariate analysis (see Table 3F)
Knoop et al. 2005; rec. # 3450 RCT (n=805); CMF (Cx) versus CEF (Tx) | | Cx | 143 | | | | | | proportional hazards
Knoop et al. 2005; rec. # 3450 RCT (n=805); CMF (Cx) versus CEF (Tx) | OS (HER2-) | Tx | 249 | | | | | | | | Cox | 0.23 | 0.82 (0.59–1.13)
Knoop et al. 2005; rec. # 3450 RCT (n=805); CMF (Cx) versus CEF (Tx) | | Cx | 293 | | | | | | proportional hazards
Knoop et al. 2005; rec. # 3450 RCT (n=805); CMF (Cx) versus CEF (Tx) | TTP | Tx
Knoop et al. 2005; rec. # 3450 RCT (n=805); CMF (Cx) versus CEF (Tx) | | Cx
Knoop et al. 2005; rec. # 3450 RCT (n=805); CMF (Cx) versus CEF (Tx) | PFS | Tx
Knoop et al. 2005; rec. # 3450 RCT (n=805); CMF (Cx) versus CEF (Tx) | | Cx
Knoop et al. 2005; rec. # 3450 RCT (n=805); CMF (Cx) versus CEF (Tx) | RFS (HER2^+^) | Tx | 120 | | | | | | | | Cox | 0.10 | 0.75 (0.53–1.06)
Knoop et al. 2005; rec. # 3450 RCT (n=805); CMF (Cx) versus CEF (Tx) | | Cx | 143 | | | | | | proportional hazards
Knoop et al. 2005; rec. # 3450 RCT (n=805); CMF (Cx) versus CEF (Tx) | RFS (HER2^-^) | Tx | 249 | | | | | | | | Cox | 0.10 | 0.79 (0.60–1.05)
Knoop et al. 2005; rec. # 3450 RCT (n=805); CMF (Cx) versus CEF (Tx) | | Cx | 293 | | | | | | proportional hazards
Knoop et al. 2005; rec. # 3450 RCT (n=805); CMF (Cx) versus CEF (Tx) | DFS | Tx
Knoop et al. 2005; rec. # 3450 RCT (n=805); CMF (Cx) versus CEF (Tx) | | Cx
Knoop et al. 2005; rec. # 3450 RCT (n=805); CMF (Cx) versus CEF (Tx) | DSS | Tx
| Cx
Dressler et al. 2005, rec. # 4280; Thor et al. 1998, rec. # 40880 separate survival curves show similar results for HER2 status by IHC, FISH, and PCR; only abstracted data for HER2 by IHC | Outcome | Grp | N | Med (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | | Test | p | HR (95%CI) | Comments
Dressler et al. 2005, rec. # 4280; Thor et al. 1998, rec. # 40880 separate survival curves show similar results for HER2 status by IHC, FISH, and PCR; only abstracted data for HER2 by IHC | OS HER2^+^ | high | 44 | >108 | | ~97% | | ~97% | 93% (86–100) | | | | | Comments
Dressler et al. 2005, rec. # 4280; Thor et al. 1998, rec. # 40880 separate survival curves show similar results for HER2 status by IHC, FISH, and PCR; only abstracted data for HER2 by IHC | by IHC | mod | 43 | ~87 | | ~93% | | ~66% | 58% (47–75) | | | | | Comments
Dressler et al. 2005, rec. # 4280; Thor et al. 1998, rec. # 40880 separate survival curves show similar results for HER2 status by IHC, FISH, and PCR; only abstracted data for HER2 by IHC | | low | 40 | ~96 | | ~90% | | ~66% | 63% (49–80) | | | | | Comments
Dressler et al. 2005, rec. # 4280; Thor et al. 1998, rec. # 40880 separate survival curves show similar results for HER2 status by IHC, FISH, and PCR; only abstracted data for HER2 by IHC | OS HER2^-^ | high | 134 | ~100 | | ~93% | | ~80% | 74% (67–81) | | | | | Comments
Dressler et al. 2005, rec. # 4280; Thor et al. 1998, rec. # 40880 separate survival curves show similar results for HER2 status by IHC, FISH, and PCR; only abstracted data for HER2 by IHC | by IHC | mod | 124 | >108 | | ~96% | | ~86% | 78% (80–92) | | | | | Comments
Dressler et al. 2005, rec. # 4280; Thor et al. 1998, rec. # 40880 separate survival curves show similar results for HER2 status by IHC, FISH, and PCR; only abstracted data for HER2 by IHC | | low | 138 | ~100 | | ~93% | | ~80% | 74% (67–81) | | | | | Comments
Dressler et al. 2005, rec. # 4280; Thor et al. 1998, rec. # 40880 separate survival curves show similar results for HER2 status by IHC, FISH, and PCR; only abstracted data for HER2 by IHC | PFS | Tx | | | | | | | | | | | | Comments
Dressler et al. 2005, rec. # 4280; Thor et al. 1998, rec. # 40880 separate survival curves show similar results for HER2 status by IHC, FISH, and PCR; only abstracted data for HER2 by IHC | | Cx | | | | | | | | | | | | Comments
Dressler et al. 2005, rec. # 4280; Thor et al. 1998, rec. # 40880 separate survival curves show similar results for HER2 status by IHC, FISH, and PCR; only abstracted data for HER2 by IHC | DFS HER2^+^ | high | 44 | >108 | | ~97% | | ~90% | 87% (74–96) | | | | | Comments
Dressler et al. 2005, rec. # 4280; Thor et al. 1998, rec. # 40880 separate survival curves show similar results for HER2 status by IHC, FISH, and PCR; only abstracted data for HER2 by IHC | by IHC | mod | 43 | ~36 | | ~60% | | ~47% | 47% (34–64) | | | | | Comments
Dressler et al. 2005, rec. # 4280; Thor et al. 1998, rec. # 40880 separate survival curves show similar results for HER2 status by IHC, FISH, and PCR; only abstracted data for HER2 by IHC | | low | 40 | ~66 | | ~65% | | ~58% | 53% (39–71) | | | | | Comments
Dressler et al. 2005, rec. # 4280; Thor et al. 1998, rec. # 40880 separate survival curves show similar results for HER2 status by IHC, FISH, and PCR; only abstracted data for HER2 by IHC | DFS HER2^-^ | high | 134 | >108 | | ~83% | | ~70% | 64% (56–73) | | | | | Comments
Dressler et al. 2005, rec. # 4280; Thor et al. 1998, rec. # 40880 separate survival curves show similar results for HER2 status by IHC, FISH, and PCR; only abstracted data for HER2 by IHC | by IHC | mod | 124 | >108 | | ~83% | | ~70% | 65% (57–74) | | | | | Comments
Dressler et al. 2005, rec. # 4280; Thor et al. 1998, rec. # 40880 separate survival curves show similar results for HER2 status by IHC, FISH, and PCR; only abstracted data for HER2 by IHC | | low | 138 | ~90 | | ~78% | | ~63% | 59% (51–68) | | | | | Comments
Dressler et al. 2005, rec. # 4280; Thor et al. 1998, rec. # 40880 separate survival curves show similar results for HER2 status by IHC, FISH, and PCR; only abstracted data for HER2 by IHC | DSS | Tx | | | | | | | | | | | | Comments
| Cx
Del Mastro et al. 2004, 2005; rec # 48020 Tx = FEC_14_ Cx = FEC_21_ | Outcome | Grp | N | Med (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | | Test | p | HR (95%CI) | Comments
Del Mastro et al. 2004, 2005; rec # 48020 Tx = FEC_14_ Cx = FEC_21_ | OS (HER2+) | Tx | 50 | >72 | ~100% | ~100% | ~96% | ~92% | 89.9% | | prop hazards | 0.22 | 0.59 (0.26–1.37) | for all FEC_14_, HER2^+^ vs HER2^-^: EFS, HR=1.21
Del Mastro et al. 2004, 2005; rec # 48020 Tx = FEC_14_ Cx = FEC_21_ | | Cx | 53 | >72 | ~98% | ~89% | ~85% | ~81% | 75.1%
Del Mastro et al. 2004, 2005; rec # 48020 Tx = FEC_14_ Cx = FEC_21_ | OS (HER2-) | Tx | 320 | >84 | ~100% | ~99% | ~96% | ~95% | 91.9% | | prop hazards | 0.34 | 0.79 (0.49–1.28) | (0.65–2.24) p=0.54;
Del Mastro et al. 2004, 2005; rec # 48020 Tx = FEC_14_ Cx = FEC_21_ | | Cx | 308 | >84 | ~100% | ~99% | ~96% | ~94% | 90.7% | | | | | OS, HR=1.85 (0.88–3.89), p=0.103
Del Mastro et al. 2004, 2005; rec # 48020 Tx = FEC_14_ Cx = FEC_21_ | PFS | Tx
Del Mastro et al. 2004, 2005; rec # 48020 Tx = FEC_14_ Cx = FEC_21_ | | Cx
Del Mastro et al. 2004, 2005; rec # 48020 Tx = FEC_14_ Cx = FEC_21_ | EFS (HER2^+^) | Tx | 50 | >72 | ~100% | ~98% | ~85% | 79% | 77.7% | | prop hazards | 0.092 | 0.54 (0.27–1.11) | for all FEC_21_, HER2+ vs HER2^-^: EFS, HR=2.07
Del Mastro et al. 2004, 2005; rec # 48020 Tx = FEC_14_ Cx = FEC_21_ | | Cx | 53 | >72 | ~91% | ~82% | ~68% | ~67% | 62.5%
Del Mastro et al. 2004, 2005; rec # 48020 Tx = FEC_14_ Cx = FEC_21_ | EFS (HER2^-^) | Tx | 320 | >84 | ~100% | ~93% | ~90% | ~85% | 81.5% | | prop hazards | 0.57 | 0.91 (0.65–1.27) | (1.27–3.38), p=0.003;
Del Mastro et al. 2004, 2005; rec # 48020 Tx = FEC_14_ Cx = FEC_21_ | | Cx | 308 | >84 | ~98% | ~93% | ~87% | ~83% | 80.9% | | | | | OS, HR2.47 (1.34–4.57), p=0.004
Del Mastro et al. 2004, 2005; rec # 48020 Tx = FEC_14_ Cx = FEC_21_ | DSS | Tx
| Cx
Tanner et al. 2006; rec. # 1820 only reported statistical comparisons of FEC versus CTCb, not HER2+ versus HER2- in same treatment arm | Outcome | Grp | N | Med (mos) | 2 yr | 3 yr | 4 yr | 5 yr | 6 yr | | Test | p | HR (95%CI) | Comments
Tanner et al. 2006; rec. # 1820 only reported statistical comparisons of FEC versus CTCb, not HER2+ versus HER2- in same treatment arm | OS | HER2^+^ | 56 | ~54 | ~79% | ~64% | ~58% | ~46% | ~41% | | not reported | | | Comments
Tanner et al. 2006; rec. # 1820 only reported statistical comparisons of FEC versus CTCb, not HER2+ versus HER2- in same treatment arm | | HER2^-^ | 124 | >84 | ~94 | ~83% | ~74% | ~68% | ~64% | | | | | Comments
Tanner et al. 2006; rec. # 1820 only reported statistical comparisons of FEC versus CTCb, not HER2+ versus HER2- in same treatment arm | TTP | Tx | | | | | | | | | | | | Comments
Tanner et al. 2006; rec. # 1820 only reported statistical comparisons of FEC versus CTCb, not HER2+ versus HER2- in same treatment arm | | Cx | | | | | | | | | | | | Comments
Tanner et al. 2006; rec. # 1820 only reported statistical comparisons of FEC versus CTCb, not HER2+ versus HER2- in same treatment arm | PFS | Tx | | | | | | | | | | | | Comments
Tanner et al. 2006; rec. # 1820 only reported statistical comparisons of FEC versus CTCb, not HER2+ versus HER2- in same treatment arm | | Cx | | | | | | | | | | | | Comments
Tanner et al. 2006; rec. # 1820 only reported statistical comparisons of FEC versus CTCb, not HER2+ versus HER2- in same treatment arm | RFS | HER2^+^ | 56 | ~48 | ~68% | ~62% | ~50% | ~46% | ~46% | | not reported | | | Comments
Tanner et al. 2006; rec. # 1820 only reported statistical comparisons of FEC versus CTCb, not HER2+ versus HER2- in same treatment arm | | HER2^-^ | 124 | >84 | ~84% | ~74% | ~67% | ~66% | ~65% | | | | | Comments
Tanner et al. 2006; rec. # 1820 only reported statistical comparisons of FEC versus CTCb, not HER2+ versus HER2- in same treatment arm | DFS | Tx | | | | | | | | | | | | Comments
| Cx
Hayes et al. 2007; rec. # 47610 AC→P (Tx) vs. AC alone (Cx) HER2 status based on CB11 IHC test results; data from K-M curves of Fig. 1; Groups 1 & 2 randomly and separately selected from n=3121 in CALGB 9344 RCT | Outcome | Grp | N | Med (mos) | 3 yr | | 6 yr | 9 yr | | | Test | p | HR (95%CI) | Comments:
| OS HER2^+^ | Tx | | not reached | ~87% | | ~75% | ~70% | | | Cox | 0.17 | 0.61 | HR's & p's: interaction of HER2+ status with effect of adding paclitaxel (from Table 2); for Groups 1 & 2 pooled, n=1322: HR for OS = 0.57, p = 0.01
| Group 1 | Cx | | ~108 | ~75% | | ~62% | ~50% | | | multivariate regression
| OS HER2^-^ | Tx | | not reached | ~87% | | ~77% | ~70%
| Group 1 | Cx | | not reached | ~87% | | ~74% | ~66%
| OS HER2^+^ | Tx | | not reached | ~92% | | ~78% | ~78% | | | Cox | 0.03 | 0.52
| Group 2 | Cx | | ~72 | ~70% | | ~50% | ~49% | | | multivariate regression
| OS HER2^-^ | Tx | | not reached | ~92% | | ~80% | ~68%
| Group 2 | Cx | | not reached | ~85% | | ~76% | ~63%
| DFS HER2^+^ | Tx | | not reached | ~80% | | ~69% | ~62% | | | Cox | 0.15 | 0.63 | Groups 1 & 2, pooled HR for DFS = 0.59, p = 0.01
| Group 1 | Cx | | ~66 | ~60% | | ~48% | ~47% | | | multivariate regression
| DFS HER2^-^ | Tx | | not reached | ~80% | | ~70% | ~65%
| Group 1 | Cx | | ~126 | ~80% | | ~67% | ~55%
| DFS HER2^+^ | Tx | | not reached | ~87% | | ~72% | ~67% | | | Cox | 0.03 | 0.52
| Group 2 | Cx | | ~48 | ~53% | | ~48% | ~45% | | | multivariate regression
| DFS HER2^-^ | Tx | | not reached | ~80% | | ~75% | ~69%
Group 2 | Cx | | ~126 | ~78% | | ~65% | ~60%
Martin et al. 2005; rec # 47650 Tx = DAC Cx = FAC | Outcome | Grp | N | Med (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | | Test | p | HR (95%CI) | Comments
Martin et al. 2005; rec # 47650 Tx = DAC Cx = FAC | OS | Tx
Martin et al. 2005; rec # 47650 Tx = DAC Cx = FAC | | Cx
Martin et al. 2005; rec # 47650 Tx = DAC Cx = FAC | TTP | Tx
Martin et al. 2005; rec # 47650 Tx = DAC Cx = FAC | | Cx
Martin et al. 2005; rec # 47650 Tx = DAC Cx = FAC | PFS | Tx
Martin et al. 2005; rec # 47650 Tx = DAC Cx = FAC | | Cx
Martin et al. 2005; rec # 47650 Tx = DAC Cx = FAC | DFS HER2^+^ | Tx | 155 | | | | | | | | Cox | | 0.60 (0.41–0.88) | K-M DFS curves not shown separately by HER2 status;
Martin et al. 2005; rec # 47650 Tx = DAC Cx = FAC | | Cx | 164 | | | | | | | | prop hzrds models | | | p values not reported
Martin et al. 2005; rec # 47650 Tx = DAC Cx = FAC | DFS HER2^-^ | Tx | 475 | | | | | | | | | | 0.76 (0.59–1.00)
Martin et al. 2005; rec # 47650 Tx = DAC Cx = FAC | | Cx | 468
Martin et al. 2005; rec # 47650 Tx = DAC Cx = FAC | DFS HER2 | Tx | 115 | | | | | | | | | | 0.72 (0.45–1.17)
unknown | Cx | 114
Neoadjuvant (Pre-operative) Chemotherapy
Learn et al. 2005; rec. # 47640 | did not report time-to-event outcome
Arriola et al. 2006; rec # 950 | did not report time-to-event outcomes
Park et al. 2003; rec # 9960 | did not report time-to-event outcomes
Zhang et al. 2003; rec # 9820 FAC neoadjuvant chemoTx, n=97; n=78 also given post-op chemoTx (44, paclitaxel; 26, FAC; 8, only doxorubicin) 8 lost to F/U after locoregional Tx | Outcome | Grp | N | Med (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | | Test | p | HR (95%CI) | Comments
Zhang et al. 2003; rec # 9820 FAC neoadjuvant chemoTx, n=97; n=78 also given post-op chemoTx (44, paclitaxel; 26, FAC; 8, only doxorubicin) 8 lost to F/U after locoregional Tx | OS | Tx | | | | | | | | | | | | Comments
Zhang et al. 2003; rec # 9820 FAC neoadjuvant chemoTx, n=97; n=78 also given post-op chemoTx (44, paclitaxel; 26, FAC; 8, only doxorubicin) 8 lost to F/U after locoregional Tx | | Cx | | | | | | | | | | | | Comments
Zhang et al. 2003; rec # 9820 FAC neoadjuvant chemoTx, n=97; n=78 also given post-op chemoTx (44, paclitaxel; 26, FAC; 8, only doxorubicin) 8 lost to F/U after locoregional Tx | TTP | Tx | | | | | | | | | | | | Comments
Zhang et al. 2003; rec # 9820 FAC neoadjuvant chemoTx, n=97; n=78 also given post-op chemoTx (44, paclitaxel; 26, FAC; 8, only doxorubicin) 8 lost to F/U after locoregional Tx | | Cx | | | | | | | | | | | | Comments
Zhang et al. 2003; rec # 9820 FAC neoadjuvant chemoTx, n=97; n=78 also given post-op chemoTx (44, paclitaxel; 26, FAC; 8, only doxorubicin) 8 lost to F/U after locoregional Tx | PFS | Tx | | | | | | | | | | | | Comments
Zhang et al. 2003; rec # 9820 FAC neoadjuvant chemoTx, n=97; n=78 also given post-op chemoTx (44, paclitaxel; 26, FAC; 8, only doxorubicin) 8 lost to F/U after locoregional Tx | | Cx | | | | | | | | | | | | Comments
Zhang et al. 2003; rec # 9820 FAC neoadjuvant chemoTx, n=97; n=78 also given post-op chemoTx (44, paclitaxel; 26, FAC; 8, only doxorubicin) 8 lost to F/U after locoregional Tx | RFS | Tx | | | | | | | | | | | | Comments
Zhang et al. 2003; rec # 9820 FAC neoadjuvant chemoTx, n=97; n=78 also given post-op chemoTx (44, paclitaxel; 26, FAC; 8, only doxorubicin) 8 lost to F/U after locoregional Tx | | Cx | | | | | | | | | | | | Comments
Zhang et al. 2003; rec # 9820 FAC neoadjuvant chemoTx, n=97; n=78 also given post-op chemoTx (44, paclitaxel; 26, FAC; 8, only doxorubicin) 8 lost to F/U after locoregional Tx | DFS | HER2+ | 28 | 48 (for all patients) | ~90% | ~83% | ~60% | ~45% | | | not specified | NS | not reported | Comments
| HER2- | 69 | | ~90% | ~80% | ~70% | ~60%
Tulbah et al. 2002; rec #11560 | Outcome | Grp | N | Med (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | | Test | p | HR (95%CI) | Comments
Tulbah et al. 2002; rec #11560 | OS | HER2^+^ | 22 | not reached | ~95% | ~79% | ~66% | ~66% | | | log | 0.31 | | if HER2+ = IHC 2+ or 3+ OS favored HER2-: 90% vs 79%, p=0.051
Tulbah et al. 2002; rec #11560 | | HER2^-^ | 32 | not reached | ~97% | ~97% | ~72% | ~72% | | | rank
Tulbah et al. 2002; rec #11560 | TTP | Tx
Tulbah et al. 2002; rec #11560 | | Cx
Tulbah et al. 2002; rec #11560 | DFS | HER2+ | 21 | 34.5±7.8 | ~88% | ~75% | ~75% | 0 | | | log | 0.43 | | if HER2+ = IHC 2+ or 3+ difference in DFS still not statistically significant (p=0.09)
Tulbah et al. 2002; rec #11560 | | HER2- | 31 | (all 52 pts) | ~92% | ~83% | ~52% | ~52% | | | rank
Tulbah et al. 2002; rec #11560 | DSS | Tx
| Cx
Tinari et al. 2006; rec # 2300 | did not report time-to-event outcome by HER2 status
Chemotherapy for Advanced or Metastatic Disease
390, Harris et al 2006 | Outcome | Grp | N | Med (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | 10yr | Test | p | HR (95%CI) | Comments
390, Harris et al 2006 | OS | CB11+ | 30 | 11.3 | | | | | | | Log | 0.14 | | Comments
390, Harris et al 2006 | | CB11- | 126 | 13.1 | | | | | | | rank | | | Comments
390, Harris et al 2006 | | | | | | | | | | | | | | Comments
390, Harris et al 2006 | | FISH+ | 37 | 10.9 | | | | | | | Log | 0.26 | | Comments
390, Harris et al 2006 | | FISH- | 109 | 13.1 | | | | | | | rank | | | Comments
390, Harris et al 2006 | HercepTest | 2+/3+ | 46 | 11.5 | | | | | | | Log | 0.84 | | Comments
HercepTest | 0/1+ | 105 | 13.2 | | | | | | | rank
5970, Di Leo et al 2004 Grp 1: A Grp 2: T | Outcome | Grp | N | Med (mos) | 6 mos | 1 yr | 1.5 yr | 2 yr | 2.5 yr | | Test | p | HR (95%CI) | Comments
5970, Di Leo et al 2004 Grp 1: A Grp 2: T | OS HER2+ | 1 | 15 | 10.8 | ~.85 | ~.3 | No line | No line | No line | | Cox | .33 | 1.47(0.68–3.15) | In full TAX 303 trial, no statistically significant differences between Tx arms with respect to OS or TTP
5970, Di Leo et al 2004 Grp 1: A Grp 2: T | | 2 | 21 | 14.4 | ~.95 | ~.6 | ~.46 | No line | No line | | regression
5970, Di Leo et al 2004 Grp 1: A Grp 2: T | OS HER2- | 1 | 63 | 16.9 | ~.8 | ~.72 | ~.5 | ~.3 | No line | | Cox | .07 | 0.64(0.40–1.03)
5970, Di Leo et al 2004 Grp 1: A Grp 2: T | | 2 | 50 | 12.6 | ~.8 | ~.6 | ~.32 | ~.28 | 0 | | regression
5970, Di Leo et al 2004 Grp 1: A Grp 2: T | | | | [underlined: 3 mos] | [underlined: 6 mos] | [underlined: 9 mos] | [underlined: 12 mos] | [underlined: 15 mos] | [underlined: 18 mos]
5970, Di Leo et al 2004 Grp 1: A Grp 2: T | TTP HER2+ | 1 | 15 | 4.7 ~.75 | ~.4 | ~.25 | ~.15 | ~.15 | 0 | | Cox | .73 | 0.88(0.43–1.82)
5970, Di Leo et al 2004 Grp 1: A Grp 2: T | | 2 | 21 | 7.0 ~.75 | ~.6 | ~.15 | ~.1 | ~0 | No line | | regression
5970, Di Leo et al 2004 Grp 1: A Grp 2: T | TTP HER2- | 1 | 63 | 5.9 ~.74 | ~.5 | ~.35 | ~.25 | ~.15 | <.1 | | Cox | .22 | 0.77(0.52–1.16)
5970, Di Leo et al 2004 Grp 1: A Grp 2: T | | 2 | 50 | 5.0 ~.74 | ~.45 | ~.2 | ~.1 | <.1 | No line | | regression
5970, Di Leo et al 2004 Grp 1: A Grp 2: T | PFS | Tx
| Cx
6740, Konecny et al 2004 Grp 1: EC Grp 2: ET | Outcome | Grp | N | Med (mos) (95%CI) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | | Test | p | HR (95%CI) | Comments
6740, Konecny et al 2004 Grp 1: EC Grp 2: ET | OS | 1 | | | | | | | | | | | | Comments
6740, Konecny et al 2004 Grp 1: EC Grp 2: ET | HER2+ | | 49 | 16.4(12.1–20.1) | ~.65 | ~.3 | ~.25 | ~.25 | | | log | 0.010 | | Comments
6740, Konecny et al 2004 Grp 1: EC Grp 2: ET | HER2- | | 88 | 33.1(20.9–50.6) | ~.78 | ~.57 | ~.45 | ~.4 | | | rank | | | Comments
6740, Konecny et al 2004 Grp 1: EC Grp 2: ET | | 2 | | | | | | | | | | | | Comments
6740, Konecny et al 2004 Grp 1: EC Grp 2: ET | HER2+ | | 48 | 21.4(15.3–27.3) | ~.74 | ~.45 | ~.25 | ~.1 | | | log | 0.463 | | Comments
6740, Konecny et al 2004 Grp 1: EC Grp 2: ET | HER2- | | 90 | 27.5(17.1–35.2) | ~.7 | ~.55 | ~.35 | ~.2 | | | rank | | | Comments
6740, Konecny et al 2004 Grp 1: EC Grp 2: ET | HER2+ | 1 | 49 | 16.4(12.1–20.1) | ~.6 | ~.3 | ~.25 | ~.25 | | | log | 0.319 | | Comments
6740, Konecny et al 2004 Grp 1: EC Grp 2: ET | | 2 | 48 | 21.4(15.3–27.3) | ~.7 | ~.4 | ~.25 | ~.1 | | | rank | | | Comments
6740, Konecny et al 2004 Grp 1: EC Grp 2: ET | HER2- | 1 | 88 | 33.1(20.9–50.6) | ~.78 | ~.58 | ~.43 | ~.4 | | | log | 0.292 | | Comments
6740, Konecny et al 2004 Grp 1: EC Grp 2: ET | | 2 | 90 | 27.5(17.1–35.2) | ~.7 | ~.55 | ~.35 | ~.15 | | | rank | | | Comments
6740, Konecny et al 2004 Grp 1: EC Grp 2: ET | TTP | Tx | | | | | | | | | | | | Comments
6740, Konecny et al 2004 Grp 1: EC Grp 2: ET | | Cx | | | | | | | | | | | | Comments
6740, Konecny et al 2004 Grp 1: EC Grp 2: ET | PFS | 1 | | | | | | | | | | | | Comments
6740, Konecny et al 2004 Grp 1: EC Grp 2: ET | HER2+ | | 49 | 7.1(4.1–9.3) | ~.2 | ~.08 | ~.08 | | | | log | 0.010 | | Comments
6740, Konecny et al 2004 Grp 1: EC Grp 2: ET | HER2- | | 88 | 10.4(6.9–14.9) | ~.54 | ~.22 | ~.12 | | | | rank | | | Comments
6740, Konecny et al 2004 Grp 1: EC Grp 2: ET | | 2 | | | | | | | | | | | | Comments
6740, Konecny et al 2004 Grp 1: EC Grp 2: ET | HER2+ | | 48 | 10.5(8.1–11.9) | ~.35 | ~.1 | ~.05 | | | | log | 0.584 | | Comments
6740, Konecny et al 2004 Grp 1: EC Grp 2: ET | HER2- | | 90 | 9.6(7.5–11.3) | ~.35 | ~.15 | ~.08 | | | | rank | | | Comments
6740, Konecny et al 2004 Grp 1: EC Grp 2: ET | HER2+ | 1 | 49 | 7.1(4.1–9.3) | ~.2 | ~.08 | ~.08 | | | | log | 0.116 | | Comments
6740, Konecny et al 2004 Grp 1: EC Grp 2: ET | | 2 | 48 | 10.5(8.1–11.9) | ~.35 | ~.1 | ~.05 | | | | rank | | | Comments
6740, Konecny et al 2004 Grp 1: EC Grp 2: ET | HER2- | 1 | 88 | 10.4(6.9–14.9) | ~.47 | ~.25 | ~.1 | | | | log | 0.350 | | Comments
| 2 | 90 | 9.6(7.5–11.3) | ~.52 | ~.13 | ~.08 | | | | rank

Table IIIa-F Time to Event Outcome Regression Modeling

Study | Design/Outcome/Model | Candidate Predictors/Method to Identify Candidates | Univariate Results, Variable (p value) | Selected Predictors/Methods to Select Predictors for Multivariate Model | Proportional Hazards Assumption Assessed?/Interactions Considered? | Multivariate Model Results, Variable (p value) | Discrimination/Validation Methods/Results | Calibration/Goodness of Fit
Adjuvant Chemotherapy
Yang et al. 2003 rec. # 8840 | not reported
Gusterson et al. 2003; rec. #43690 | RCT OS & DFS Cox proportional hazards | not specified | varied by outcome & groups compared | menopausal status; tumor size; ER, PR & nodal status; grade; assigned Tx; selection method not described | not mentioned | varied by outcome & groups compared | not described | not reported
Moliterni et. al. 2003; rec. #10210 | RCT RFS, OS Cox semi-parametric | not specified | not reported | Tx; HER2 status; interaction term; T size; ER, PR, & p53 status; selection method not described | Schoenfeld plots tested prop hzrd; interaction term included | RFS: HR=0.68, p, NS; OS: HR=0.48, p=0.052 (both for Tx × HER2 interaction) | bootstrap procedure [need David's help for Results] | not certain; need David's input
Colozza et al. 2005; rec. # 3820 | RCT OS Cox model | not specified | not reported | T size; ER, PR, & HER2 status; p≤0.10 in univar. analysis | proportional hazards untested; interaction term included | RFS: HR=1.02 CI: 0.40–2.58, p, NS; OS: HR=1.61 CI: 0.64–4.01, p, NS; both for Tx × HER2 interaction | not described | not mentioned
David: Do we also need #'s for Tx & HER2 status (top 2 rows, table 5?)
Pritchard et al. 2006; rec. # 1760 interaction, Tx × HER2 status by FISH | RCT RFS, OS Cox proportional hazards | not specified | RFS: 1.79 (1.08–2.96; p=0.02) OS: 1.66 (0.97–2.85; p=0.07) | age, # + nodes ER status, surgery type, T size; selection method not described | unclear if tested prop hazards; interaction term included | RFS: HR=1.96, CI: 1.15–3.36, p=0.01 OS: HR=2.04, CI: 1.14–3.65, p=0.02 | not described | not mentioned
Knoop et al. 2005; rec. # 3450 RCT (n=805); CMF (Cx) versus CEF (Tx) | RCT RFS, OS Cox proportional hazards | age, tumor size, nodal, menopauseal & ER status, grade; method of identifying candidates not described | not reported | RFS & OS: T size, nodal & menopausal status; stratified for: grade, ER & TOP2A status; used backward selection | assumption assessed graphically & w time-depend. component; interaction term included | RFS: W_1_=0.6 p, NS (0.81) OS: W_1_=0.23 p, NS (0.63) | not described | not mentioned
[need David to check these entries]
Dressler et al. 2005, rec. # 4280; Thor et al. 1998, rec. # 40880 | 3-arm RCT; DFS, OS (only DFS reported); proportional hazards | SQRT_#N^+^, T size, menopause status, CAF dose, HER2 status, CAF dose × HER2 status interaction term | not reported | SQRT_#N^+^, T size, menopause status, CAF dose, HER2 status, CAF dose × HER2 status interaction term | proportional hazards test not mentioned; interaction term included in each proportional hazards model | HR for interaction terms: HER2 by IHC: 0.418 (0.188–0.930), p=0.0003 HER2 by FISH: 0.919 (0.814–1.038), p=0.033 HER2 by PCR 0.585 (0.253–1.352), p=0.043 | not described | not mentioned
Del Mastro et al. 2004, 2005; rec. # 48020 | RCT EFS, OS proportional hazards | Tx arm, age, ER, PR, HER2 & menopause status, tumor grade, proliferative activity | EFS, OS see Table 3E for results | step-down procedure based on likelihood ratio test; retined if p<0.15 | proportional hazards test not mentioned; interaction term included in each proportional hazards model | EFS HR, vs FEC_21_ HER2^-^: HER2^+^, 2.04; FEC_14_ HER2^-^, 0.85; HER2^+^, 0.91; p_interact_ = 0.12 OS HR vs FEC_21_ HER2^-^,: HER2^+^, 2.41; FEC_14_ HER2^-^, 0.72; HER2^+^, 1.13; p_interact_ = 0.38 | not described | not mentioned
Tanner et al. 2006; rec. # 1820 | not reported or done (only reported multivariate Cox regression analysis of outcomes by TOP2A amplification status in HER2+ subgroup)
Hayes et al. 2007; rec. # 47610 | RCT DFS, OS Cox proportional hazards | not specified | not reported | use of P; A dose; SQRT_#N^+^, T size; menopause, ER, & HER2 status; HER2^+^ × P use interaction; selection method | prop. hazards test not mentioned; interaction term included not described | DFS: HR=0.59 p=0.01 OS: HR=0.57 p=0.01 (both HR's for Groups 1 & 2 pooled) | not described | not mentioned
Martin et al. 2005; rec # 47650 | RCT DFS Cox proportional hazards | separate univariate anal. on # N^+^, ER/PR status, HER2 status, menopaus status; each adjusted for age, Tsize | see table 3E; p values not reported | not mentioned or described | prop. hazards test not mentioned; included interaction test | ratio of hazard ratios = 0.85; p=0.41 | not described | not mentioned
Neoadjuvant Chemotherapy
Learn et al. 2005; rec. # 47640 | did not report time-to-event outcomes
Arriola et al. 2006; rec # 950 | did not report time-to-event outcomes
Park et al. 2003; rec # 9960 | did not report time-to-event outcomes
Zhang et al. 2003; rec # 9820 | did not report regression modeling for time-to-event outcomes
Tulbah et al. 2002; rec # 11560 | did not report regression modeling for time-to-event outcomes
Tinari et al. 2006; rec # 2300 | did not include HER2 as predictor in regression modeling for time-to-event outcome
390, Harris et al 2006 | Cox | No info | TTF: HR(95%CI); p value HER2+ by CB11: 1.44(0.97–2.15), 0.68 HER2+ by FISH: 1.22(0.85–1.76), 0.29 HercepTest 2–3: 1.02(0.73–1.43), 0.90 HercepTest 3: 1.34(0.91–1.98), 0.14 OS: HR(95%CI); p value HER2+ by CB11: 1.34(0.91–1.99), 0.41 HER2+ by FISH: 1.24(0.86–1.79), 0.25 HercepTest 2–3: 1.04(0.74–1.46), 0.83 HercepTest 3: 1.11(0.76–1.64), 0.59 | Age, performance, ER and PR status, # met sites, disease free interval, prior adj chemo, HER2, | No | HercepTest- (0–1 vs 2–3): TTF HR=0.97 (95%CI:0.68–1.40), p=0.88; OS HR=0.93 (95%CI:0.65–1.35), p=0.71 | NR | NR
5970, Di Leo et al 2004 | Cox | candidates not specified; selected as known prognos-factors & by results of univariate analysis | reported in Table 3E;I interaction HER2*Tx for TTP NS (p=.62); HER2*Tx for OS NS (p=.10)
6740, Konecny et al 2004 Grp 1: EC Grp 2: ET | Cox | Not reported | RR failure Grp2/Grp1 For HER2+= 0.71(0.47–1.09, p=0.118) RR death Grp2/Grp1 For HER2+= 0.78(0.47–1.28, p=.320) RR failure Grp2/Grp1 For HER2-= 1.17(0.84–1.62, p=352) RR death Grp2/Grp1 For HER2-= 1.24(0.83–1.87, p=.294) PFS: T*HER2 p=0.090; OS: T*HER2 p=0.152 | Stepwise regression Age, histology, mets site, # mets, prior Tx, nuclear grade, ER/PR status | Both assessed | RR of failure Grp2/Grp1 for HER2+= 0.65 (0.42–1.02, p=0.062) RR death Grp2/Grp1 For HER2+= 0.60(0.36–1.02, p=0.059) RR failure Grp2/Grp1 For HER2-= 1.10(0.77–1.57, p=0.590) RR death Grp2/Grp1 For HER2+= 1.10(0.70–1.72, p=0.680) PFS: adjusted T*HER2: p=0.109 OS: adjusted T*HER2: p=0.136 | Not reported | Yes

Table IIIa-G Tumor Response and Quality of Life

Study | Tumor Response | | | | | | | | | | | | | Quality of Life
Adjuvant Chemotherapy
Yang et al. 2003; rec. # 8840 | not reported | | | | | | | | | | | | | not reported
Gusterson et al. 2003; rec. # 43690 | not reported | | | | | | | | | | | | | not reported
Moliterni et. al. 2003; rec. # 10210 | not reported | | | | | | | | | | | | | not reported
Colozza et al. 2005; rec. # 3820 | not reported | | | | | | | | | | | | | not reported
Pritchard et al. 2006; rec. # 1760 | not reported | | | | | | | | | | | | | not reported
Knoop et al. 2005; rec. # 3450 | not reported | | | | | | | | | | | | | not reported
Dressler et al. 2005, rec. # 4280 | not reported | | | | | | | | | | | | | not reported
Del Mastro et al. 2004, 2005; rec. # 48020 | not reported | | | | | | | | | | | | | not reported
Tanner et al. 2006; rec. # 1820 | not reported | | | | | | | | | | | | | not reported
Hayes et al. 2007; rec. # 47610 | not reported | | | | | | | | | | | | | not reported
Martin et al. 2005; rec # 47650 | not reported | | | | | | | | | | | | | not reported
Neoadjuvant Chemotherapy
Learn et al. 2005; rec. # 47640; n=104 classified for HER2 status | Grp | | N | pCR | ORR (cCR+cPR) | | | Test | p | | Comments: for ORR data, by multivariate analysis, AC, HER2^+^ vs HER2^-^, p=0.06; AC+D, HER2^+^ vs HER2^-^, p=0.99 | | | not reported
Learn et al. 2005; rec. # 47640; n=104 classified for HER2 status | HER2^+^, AC | | 32 | 22% | 75% | | | logistic regression | NS | | Comments: for ORR data, by multivariate analysis, AC, HER2^+^ vs HER2^-^, p=0.06; AC+D, HER2^+^ vs HER2^-^, p=0.99 | | | not reported
Learn et al. 2005; rec. # 47640; n=104 classified for HER2 status | HER2^+^, AC+D | | 9 | 22% | 78% | | | | | | Comments: for ORR data, by multivariate analysis, AC, HER2^+^ vs HER2^-^, p=0.06; AC+D, HER2^+^ vs HER2^-^, p=0.99 | | | not reported
Learn et al. 2005; rec. # 47640; n=104 classified for HER2 status | HER2^-^, AC | | 37 | 24% | 51% | | | | <0.05 | | Comments: for ORR data, by multivariate analysis, AC, HER2^+^ vs HER2^-^, p=0.06; AC+D, HER2^+^ vs HER2^-^, p=0.99 | | | not reported
HER^-^, AC+D | | 26 | 24% | 81%
Arriola et al. 2006; rec # 950 | Grp | N | pCR | PR | SD | PD | NE | Test | p | | Comments “association of with pCR” | | | not reported
Arriola et al. 2006; rec # 950 | all | 229 | 27 | | | | | Mann-Whitney | 0.013 | | Comments “association of with pCR” | | | not reported
HER2^+^
Park et al. 2003; rec # 9960 | Grp | N | pCR | PR | OR (CR+PR) | | NR (PD+NE) | | Test | | p | Comments | | not reported
Park et al. 2003; rec # 9960 | HER2^+^ | 31 | 5 (16%) | 22 (71%) | 27 (87%) | | 4 (13%) | | Fisher's exact | | 0.013 | Comments | | not reported
HER2^-^ | 36 | 0 | 17 (47%) | 17 (47%) | | 19 (53%)
Zhang et al. 2003; rec # 9820 | Grp | N | cCR+cPR | cNR | p | RR | 95%CI | pCR+MRD | ERD | p | RR | 95%CI | tests
Zhang et al. 2003; rec # 9820 | HER2^+^ | 28 | 93% | 7% | 0.14 | 1.2 | 1.1–1.4 | 18% | 82% | 0.53 | 1.4 | 0.54–3.67 | Fisher's asymptotic | not reported
Zhang et al. 2003; rec # 9820 | exact &
HER2^-^ | 69 | 78% | 22% | | | | 13% | 87%
Tulbah et al. 2002; rec # 11560 | Grp | N | pCR | PR | SD | PD | NE | Test | p | | Comments | | | not reported
Tulbah et al. 2002; rec # 11560 | HER2^+^ | 21 | 6 (29%) | | | | | | NS | | also NS if IHC 2+ and considered HER2+ | | | not reported
Tulbah et al. 2002; rec # 11560 | 3+ | | | | | | | | | | | | | not reported
HER2^-^ | 31 | 7 (23%)
Tinari et al. 2006; rec # 2300 | Grp | N | TR* | OR* | SD | PD | NE | Test | p | | Comments
Tinari et al. 2006; rec # 2300 | all | 77 | 23.4% | 72.7% | 3.9% | 0 | | | | | see Table 3H: Response Regression Modeling | | | not reported
Tinari et al. 2006; rec # 2300 | HER2^+^ | 20 57
HER2^-^ | 57
Chemotherapy for Advanced or Metastatic Disease
390, Harris et al 2006 | | N | CR+PR (%) | | p | | | | | | | | | not reported
| HER2 by CB11 | | | | 0.96
| Pos | 30 | 23
| Neg | 126 | 24
| HER2 FISH | | | | 0.70
| Pos | 37 | 22
| Neg | 109 | 25
| HercepTest | | | | 0.026
| Pos (2–3) | 46 | 35
| Neg (0–1) | 105 | 18
| HercepTest | | | | 0.98
| Pos (3) | 30 | 23
| Neg (0–2) | 121 | 23
5970, Di Leo et al 2004 Grp 1: A Grp 2: T | Grp1 | N | %(CR+PR) | | | | A versus T OR (95%CI) | p | | | | | | not reported
5970, Di Leo et al 2004 Grp 1: A Grp 2: T | HER2+ | 15 | 27 | | | HER2+ | 5.50(1.28–23.69) | 0.04 | | | | | | not reported
5970, Di Leo et al 2004 Grp 1: A Grp 2: T | HER2- | 63 | 35 | | | HER2- | 1.24(0.58–2.68) | 0.70 | | | | | | not reported
5970, Di Leo et al 2004 Grp 1: A Grp 2: T | HER2 unk | 13 | 31 | | | HER2 unk | 1.25(0.25–6.24) | 1.00 | | | | | | not reported
5970, Di Leo et al 2004 Grp 1: A Grp 2: T | All | 91 | 33 | | | All | 1.72(0.94–3.18) | 0.09 | | | | | | not reported
5970, Di Leo et al 2004 Grp 1: A Grp 2: T | HER2+ | 21 | 67 | | | (In full TAX 303 trial, response rates were 48% with docetaxel (n=161), 33% with doxorubicin (n=165), p=0.008) | | | | | | | | not reported
5970, Di Leo et al 2004 Grp 1: A Grp 2: T | HER2- | 50 | 40 | | | | | | | | | | | not reported
5970, Di Leo et al 2004 Grp 1: A Grp 2: T | HER2 unk | 14 | 36 | | | | | | | | | | | not reported
All | 85 | 46
6740, Konecny et al 2004 Grp1: EC Grp 2: ET | Grp+ | N | CR+PR(95%CI) | SD | PD | NE | Test | p | Comments | | | | | not reported
6740, Konecny et al 2004 Grp1: EC Grp 2: ET | HER2+ | 97 | 60(51–70) | | | | chi sq | 0.004 | | | | | | not reported
6740, Konecny et al 2004 Grp1: EC Grp 2: ET | HER2- | 178 | 41(34–49) | | | | | | | | | | | not reported
6740, Konecny et al 2004 Grp1: EC Grp 2: ET | Grp 1 | | | | | | | | | | | | | not reported
6740, Konecny et al 2004 Grp1: EC Grp 2: ET | HER2+ | 49 | 45(32–60) | | | | chi sq | 0.130 | | | | | | not reported
6740, Konecny et al 2004 Grp1: EC Grp 2: ET | HER2- | 88 | 33(22–43) | | | | | | | | | | | not reported
6740, Konecny et al 2004 Grp1: EC Grp 2: ET | Grp 2 | | | | | | | | | | | | | not reported
6740, Konecny et al 2004 Grp1: EC Grp 2: ET | HER2+ | 48 | 76(63–88) | | | | chi sq | 0.005 | | | | | | not reported
6740, Konecny et al 2004 Grp1: EC Grp 2: ET | HER2- | 90 | 50(39–61) | | | | | | | | | | | not reported
6740, Konecny et al 2004 Grp1: EC Grp 2: ET | HER2+ | | | | | | | | | | | | | not reported
6740, Konecny et al 2004 Grp1: EC Grp 2: ET | Grp1 | 49 | 45(32–60) | | | | chi sq | 0.004 | | | | | | not reported
6740, Konecny et al 2004 Grp1: EC Grp 2: ET | Grp2 | 48 | 76(63–88) | | | | | | | | | | | not reported
6740, Konecny et al 2004 Grp1: EC Grp 2: ET | HER2- | | | | | | | | | | | | | not reported
6740, Konecny et al 2004 Grp1: EC Grp 2: ET | Grp1 | 88 | 33(22–43) | | | | chi sq | 0.002 | | | | | | not reported
Grp2 | 90 | 50(39–61)

* OR= overall response (cPR + minimal residual disease + PR); TR = tumor response (cPR + minimal residual disease);

Table IIIa-H Response Regression Modeling

Study | Design/Outcome/Model | Candidate Predictors/Method for Identifying Candidates | Univariate Results, Variable (p value) | Selected Predictors/Methods for Selecting Predictors for Multivariate Model | Interactions Considered? | Multivariate Model Results, Variable (p value) | Discrimination/Validation Methods/Results | Calibration/Goodness of Fit
Adjuvant Chemotherapy
Yang et al. 2003 rec. # 8840 | not reported or done
Gusterson et al. 2003; rec# 43690 | not reported or done
Moliterni et. al. 2003; rec# 10210 | not reported or done
Colozza et al. 2005; rec. # 3820 | not reported or done
Pritchard et al. 2006; rec. # 1760 | not reported or done
Knoop et al. 2005; rec. # 3450 | not reported or done
Dressler et al. 2005, rec. # 4280 | not reported or done
Del Mastro et al. 2004, 2005; rec. # 48020 | not reported or done
Tanner et al. 2006; rec. # 1820 | not reported or done
Hayes et al. 2007; rec# 47610 | not reported or done
Martin et al. 2005 rec. # 47650 | not reported or done
Neoadjuvant Chemotherapy
Learn et al. 2005; rec. # 47640 | RCT ORR logistic regression | T size; nodal status; ER, PR, HER2, & p53 status; method for identifying not described | HER2^-^ ORR: 81%, AC+D 51%, AC, p<0.05; HER2^+^ ORR: 78% AC+D, 75%, AC, p=0.79 | not specified or described | not mentioned | ORR, HER2^-^ adjusted odds ratio, AC+D/AC: 3.5 (95% CI: 1.2–13.0); p<0.05 | not described | not mentioned
Arriola et al. 2006; rec # 950 | prospective series; pCR logistic regression | method not specified; ER, PR, Ki67 & HER2 status, tumor grade, histology | HER2 status & pCR: p=0.03 | forward stepwise logistic regression | not applicable? | not reported | not described | not reported
Park et al. 2003; rec # 9960 | retrospective series; response; linear regression | method not specified; HER2 & topoII amplification | HER2: p=0.013 topoII: p=0.011 | not specified | not applicable? | 95% responders in HER2/topoII co-amplified (n=18), p=0.038 | not described | not reported
Zhang et al. 2003; rec # 9820 | not reported or done
Tulbah et al. 2002; rec# 11560 | not reported or done
Tinari et al. 2006; rec # 2300 | retrospecttive series; tumor response (cPR + MRD); univariate logistic regression | method not specified; HER2 & topoII amplification; age, T size, ER & PR status, grade, Ki67 status | HER2: OR = 5.28 (95% CI: 1.57–19.6); p=0.008 | not reported | not mentioned | not reported | not described | not reported
Chemotherapy for Advanced or Metastatic Disease
390, Harris et al 2006 | not reported or done
5970, Di Leo et al 2004 | RCT; ORR; logistic regression | candidates: KPS, # mets, visceral involvement, HER2 status; selected as known prognostic factors | For HER2+ pts given docetaxel, OR=3.12 (1.11–8.80), p=.03; i.e., HER2*Tx is stat. signif. | Tx, HER2, Karnofsky score, # met sites; visceral involvement; Tx*HER2; Tx*visceral; stat. signif. in univariate analysis | Interactions included | Outcome=response Tx*HER2: OR Gp2/Gp1=3.64 (1.39–9.54); p=.01 (only SS factor). Remains SS after adjust for visceral and Tx*visceral | NR | NR
6740, Konecny et al 2004 Grp 1: EC Grp 2: ET | Logistic regression | | OR(HER2+ vs HER2-)=2.19 (95%CI: 1.31–3.65) p=0.003 OR (Grp2 vs Grp 1 for HER2+)=3.65(95%CI: 1.51–8.86); p=0.004) OR (Grp2 vs Grp1 for HER2-)=2.07 (95%CI: 1.10–3.90, p=0.002) Interaction Tx*HER2: P=0.308 | | Interactions included | Adjusted interaction Tx*HER2: p=0.256 OR (Grp2 Vs Grp 1 For HER2+)=3.64 (95% CI: 1.48–8.92; P=0.005) OR (Grp2 Vs Grp 1 For HER2-)=1.92(95% CI: 1.01–3.64; P=0.046) | not mentioned | yes, but not shown

Table IIIa-I Adverse Events

Toxicity Type | Study | Severity or Grade | Results
Chemotherapy
Treatment-related mortality | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Nausea | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Vomiting | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Anorexia | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Lethargy | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Neurosensory | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Hearing loss | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Cardiac ischemia | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Diminished LVEF | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Arrhythmias | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Bronchopulmonary | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Dermatologic | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Kidney | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Anemia | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Thrombocytopenia | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Leukopenia or neutropenia | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Infection | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Other | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Treatment-related mortality | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Nausea | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Vomiting | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Anorexia | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Lethargy | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Neurosensory | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Hearing loss | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Cardiac ischemia | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Diminished LVEF | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Arrhythmias | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Bronchopulmonary | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Dermatologic | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Kidney | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Anemia | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Thrombocytopenia | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Leukopenia or neutropenia | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Infection | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Other | | | F/U (mo) | Grp1 n | % | Grp2 n | %

Table IIIa-J Study Quality Ratings

Study | Prospective design | Prespecified hypotheses about relation of marker to oucome | Large, well-defined, representative study population | Marker assay methods well-described | Blinded assessment of marker in relation to outcome | Homogeneous treatment(s), either randomized or rule-based selection | Low rate of missing data (≤15%) | Sufficiently long follow-up | Well-described, well-conducted multivariate analysis of outcome: 1) clear candidate variable selection, 2) clear, appropriate model-building guidelines, 3) assumptions tested, 4) standard prognostic variables included, 5) continuous variables well handled, 6) validation
1) | 2) | 3) | 4) | 5) | 6)
Adjuvant Chemotherapy
Yang et al. 2003; rec. # 8840 | N | N | N | Y | ? | Y | Y | ? | NA
Gusterson et al. 2003; rec. # 43690 | Y | N | Y | Y | ? | Y | N | med: 6 yrs | ? | ? | N | Y | N | N
Moliterni et. al. 2003; rec. #10210 | Y | N | Y | Y | ? | Y | Y | med: 14.8 yrs | ? | ? | Y | N | ? | Y
Colozza et al. 2005; rec. # 3820 | Y | N | Y | Y | Y | Y | N | med: 8 yrs | ? | ? | N | N | ? | N
Pritchard et al. 2006; rec. # 1760 | Y | N | Y | Y | ? | Y | Y | med: 10 yrs | ? | ? | ? | ? | ? | N
Knoop et al. 2005; rec. # 3450 | Y | N | Y | Y | ? | Y | N | med: 10 yrs | ? | ? | Y | ? | ? | N
Dressler et al. 2005, rec. # 4280; Thor et al. 1998, rec. # 40880 | Y | Y | Y | Y | Y | Y | N | med: 9 yrs | Y | ? | ? | N | Y | N
Del Mastro et al. 2004, 2005; rec. # 48020 | Y | N | Y | Y | Y | Y | N | med: 6.7 yrs | ? | ? | ? | ? | ? | ?
Tanner et al. 2006; rec. # 1820 | Y | N | Y | Y | Y | Y | N | ? | NA
Hayes et al. 2007; rec. # 47610 | Y | Y | Y | Y | Y | Y | Y | med: ~10 yrs | ? | ? | ? | ? | ? | ?
Martin et al. 2005; rec # 47650 | Y | Y | Y | N | ? | Y | Y | med: 4.6 yrs | ? | ? | ? | ? | ? | ?
Neoadjuvant (Pre-operative) Chemotherapy
Learn et al. 2005; rec. # 47640 | Y | N | N | N | ? | Y | N | pCR at resection | ? | ? | NA | ? | ? | ?
Arriola et al. 2006; rec # 950 | Y | Y | Y | Y | ? | Y | Y | pCR at resection | ? | ? | NA | ? | ? | ?
Park et al. 2003; rec # 9960 | N | N | N | Y | ? | Y | Y | pCR at resection | ? | ? | ? | ? | ? | ?
Zhang et al. 2003; rec # 9820 | N | N | N | N | ? | Y | Y | pCR at resection | NA
Tulbah et al. 2002; rec # 11560 | N | N | N | Y | Y | Y | Y | pCR at resection | NA
Tinari et al. 2006; rec # 2300 | N | N | N | Y | Y | Y | Y | pCR at resection | ? | ? | NA | Y | ? | ?
Chemotherapy for Advanced or Metastatic Disease
390, Harris et al 2006 | Y | N | Y | Y | Y | Y | N | med: 8.3 yrs | N | N | N | Y | ? | N
5970, Di Leo et al 2004 | Y | N | Y | Y | Y | Y | N | med: 23 months | N | N | N | ? | ? | N
6740, Konecny et al 2004 | Y | N | Y | Y | ? | Y | N | ? | N | N | Y | Y | ? | N

Data Abstraction Table

Table IIIb-A Design, Enrollment and Treatment

Study | Design | Therapeutic Setting | n, Enrolled (Randomized) | n, Evaluated | n, Withdrawn (Lost to F/U) | Treatment Regimen (Agents)
Neoadjuvant Hormonal Therapy
None
Adjuvant Hormonal Therapy
Ryden et al 2005, multicenter, Sweden, 1986-1991 | RCT (secondary analysis) | Stage II invasive cancer, premenopausal or <50 years old. Includes HR+ and HR- | 564 | 428 | 136 (64, no specimens; 72, not assessable by IHC). Another 55 not assessable by FISH. Baseline prognostic factors similar in groups with or without specimens. | TAM for 2 yrs vs no TAM; also mastectomy or breast-conserving surgery + radiotherapy <2% pts received additional adjuvant chemotherapy (polychemotherapy, n=8; goserelin, n=1). Evenly distributed across arms.
Knoop et al. 2001, 27 sites, all in Denmark?, 8/77–11/82 | RCT (secondary analysis of Danish Breast Cancer Cooperative Group's 77c protocol) | Adjuvant, postmenopausal, “high risk” (positive axillary lymph nodes, tumor > 5 cm, skin or deep facia involvement) (Note: eligibility did not depend on hormone receptor status) | 1716 | 1515 | 201 (167, no specimens; 33, unevaluable ; 1,,unaccounted for. Baseline prognostic factors & outcomes similar in groups with or without specimens.) | TAM thrice daily for 1 year vs observation. All patients treated with mastectomy, lower ALND, and radiotherapy. 8% of the TAM pts were HER2-positive, vs. 14% of the observation arm (p=0.001) (per email from Dr. Knoop)
Metastatic Hormonal Therapy
Arpino et al. 2004, multicenter, US?, 1982-1987 | Prospective uncontrolled, SWOG protocol 8228 and ancillary study 9314 | First-line Tx for metastatic disease, ER+; prior adjuvant TAM or chemo completed > 3 mos before relapse | 349 | 136 | 213 (134, no specimens; 7, inevaluable specimens; 4, lost to F/U, 68, assays unsuccessful) | TAM twice daily until disease progression (failure), 10 mg (n=56) or 10 mg/m^2^ (n=149)

Table IIIb-B Patient Characteristics

Study | Age | | | Race (%) | | | Disease Stage | | | Disease Stage | | | | Performance Status | | | Comorbidities or Other Prognostic Factors
Neoadjuvant Hormonal Therapy
None
Adjuvant Hormonal Therapy
Ryden et al 2005 | | TAM | Cx | Not reported | | | Tumor size | | | Lymph node status(%) | | | | Not reported | | | | TAM | Cx
Ryden et al 2005 | Med | 45 | 45 | Not reported | | | | TAM | Cx | | TAM | Cx | p | Not reported | | | ER-/PR- | 30 | 26
Ryden et al 2005 | Rge | 25–57 | 26–57 | Not reported | | | Med | 25 | 22 | Neg | 30 | 26 | 0.4 | Not reported | | | ER-/PR+ | 8 | 10
Ryden et al 2005 | | | | Not reported | | | | (p=0.03) | | 1+-3+ | 50 | 49 | | Not reported | | | ER+/PR- | 4 | 5
Ryden et al 2005 | | | | Not reported | | | Rge | 5–75 | 2–50 | ≥4+ | 20 | 24 | | Not reported | | | ER+/PR+ | 54 | 57
Ryden et al 2005 | | | | Not reported | | | | | | Unk | <1 | <1 | | Not reported | | | | P=0.6
Ryden et al 2005 | | | | Not reported | | | | | | Nottingham histologic grade (%) | | | | Not reported | | | Not done | 4 | 2
Ryden et al 2005 | | | | Not reported | | | | | | | TAM | Cx | p | Not reported
Ryden et al 2005 | | | | Not reported | | | | | | 1 | 10 | 12 | 0.6 | Not reported
Ryden et al 2005 | | | | Not reported | | | | | | 2 | 39 | 44 | | Not reported
Ryden et al 2005 | | | | Not reported | | | | | | 3 | 45 | 42 | | Not reported
| | | | | | Not Done | 6 | 2
Knoop et al. 2001 | | All | % HER2+ in each age grp | Not reported | | | Tumor size(%) | | | Degree of anaplasia (%) | | | | Not reported | | | | All | % HER2+ in each group
Knoop et al. 2001 | <50 | <1 | 14 | Not reported | | | <20 mm | | 19 | I | | 26 | | Not reported | | | ER- | 34 | 32
Knoop et al. 2001 | 50–59 | 22 | 26 | Not reported | | | 21–50 mm | | 56 | II | | 47 | | Not reported | | | ER+ | 66 | 11
Knoop et al. 2001 | 60–69 | 45 | 18 | Not reported | | | >50 mm | | 25 | III | | 15 | | Not reported | | | | | p=0.001
Knoop et al. 2001 | 70–79 | 30 | 15 | Not reported | | | NR | | <1 | Other | | 11 | | Not reported | | | PR- | 57 | 27
Knoop et al. 2001 | 80–89 | 3 | 4 | Not reported | | | Med=40 mm Rge=0–250 mm | | | NR | | 1 | | Not reported | | | PR+ | 43 | 7
Knoop et al. 2001 | | | p=.001 | Not reported | | | | | | | | | | Not reported | | | | | p=0.001
med for all=66 range for all=45–88
Metastatic Hormonal Therapy
Arpino et al. 2004 | | Her2+ | Her2- | | Grp1 | Grp2 | | Grp1 | Grp2 | | | Grp1 | Grp2 | Scale | Grp1 | Grp2 | | Her2+ | Her2-
Arpino et al. 2004 | Age | | | | not reported | | I | not reported | | MnT | | not reported | | not reported | | | ER+ | 100% | 100%
Arpino et al. 2004 | <65 | 66% | 57% | B | not reported | | II | not reported | | T1 | | not reported | | not reported | | | PR+ | 78% | 96%
Arpino et al. 2004 | ≥65 | 34% | 43% | W | not reported | | III | not reported | | T2 | | not reported | | not reported | | | PR- | 19% | 4%
Arpino et al. 2004 | | | | H | not reported | | IV | not reported | | T3 | | not reported | | not reported
Arpino et al. 2004 | pre | 16% | 12% | A | not reported | | Unk | not reported | | T4 | | not reported | | not reported
Arpino et al. 2004 | post | 84% | 88% | O | not reported | | | not reported | | N0 | | not reported | | not reported
Arpino et al. 2004 | | | | | not reported | | | not reported | | N1 | | not reported | | not reported
Arpino et al. 2004 | | | | | not reported | | | not reported | | N2 | | not reported | | not reported
Arpino et al. 2004 | | | | | not reported | | | not reported | | N3 | | not reported | | not reported
| | | | | Unk

* p<.05

Table IIIb-C HER2 Measurement Methods

Study | Assays (Name) | | Criteria for Positivity | | Test Results (%) | | Comments
Neoadjuvant Hormonal Therapy
None
Adjuvant Hormonal Therapy
Ryden et al 2005 | FISH | Ventana Medical Systems, Tucson, AZ | FISH | 6+ signals/tumor cell | Pos | 13 | Correlation between IHC 3+ and Fish amplification, r=0.82, p<0.001; κ=0.84. 8% of ER+ tumors were HER2 3+ or HER2 amplified. Among HER2 2+ tumors, 1 was amplified.
| | | | | Neg | 87 | Correlation between IHC 3+ and Fish amplification, r=0.82, p<0.001; κ=0.84. 8% of ER+ tumors were HER2 3+ or HER2 amplified. Among HER2 2+ tumors, 1 was amplified.
| IHC | Pathway CB-11, 760–2694 (Ventana Medical Systems, Inc) | IHC | HercepTest 3+ | 3+ | 15 | Correlation between IHC 3+ and Fish amplification, r=0.82, p<0.001; κ=0.84. 8% of ER+ tumors were HER2 3+ or HER2 amplified. Among HER2 2+ tumors, 1 was amplified.
| | | | | 2+ | 9 | Correlation between IHC 3+ and Fish amplification, r=0.82, p<0.001; κ=0.84. 8% of ER+ tumors were HER2 3+ or HER2 amplified. Among HER2 2+ tumors, 1 was amplified.
| | | | | 1+ | 17 | Correlation between IHC 3+ and Fish amplification, r=0.82, p<0.001; κ=0.84. 8% of ER+ tumors were HER2 3+ or HER2 amplified. Among HER2 2+ tumors, 1 was amplified.
| | | | | 0 | 59
Knoop et al. 2001 | FISH | not done | FISH | | Pos | 18 | Of 18% positive, 40% were low + and 60%, hi +.
| IHC | Polyclonal, code #A485, Dako | IHC | Description unclear But appears cases high positive if ≥50% cancer Cells w/ membrane staining, roughly comparable to HercepTest 3+. Membrane staining <50% tumor cells called low positive HER2. | Equiv | | Of 18% positive, 40% were low + and 60%, hi +.
| | | | Description unclear But appears cases high positive if ≥50% cancer Cells w/ membrane staining, roughly comparable to HercepTest 3+. Membrane staining <50% tumor cells called low positive HER2. | Neg | 82 | Of 18% positive, 40% were low + and 60%, hi +.
| | | | Description unclear But appears cases high positive if ≥50% cancer Cells w/ membrane staining, roughly comparable to HercepTest 3+. Membrane staining <50% tumor cells called low positive HER2. | 3+ | | Of 18% positive, 40% were low + and 60%, hi +.
| | | | Description unclear But appears cases high positive if ≥50% cancer Cells w/ membrane staining, roughly comparable to HercepTest 3+. Membrane staining <50% tumor cells called low positive HER2. | 2+ | | Of 18% positive, 40% were low + and 60%, hi +.
| | | | Description unclear But appears cases high positive if ≥50% cancer Cells w/ membrane staining, roughly comparable to HercepTest 3+. Membrane staining <50% tumor cells called low positive HER2. | 1+ | | Of 18% positive, 40% were low + and 60%, hi +.
| | | | 0
Metastatic Hormonal Therapy
Arpino et al. 2004 | FISH | PathVysion HER-2/neu DNA Probe (Visis Inc, Downer's Grove, IL) | FISH | HER-2/CEP17 ratio ≥2 | Pos | 24 | 2 “readers” for FISH; 1 “reader” for IHC Results using IHC reported elsewhere^5^ concordance: 85%
| IHC | Monoclonal antibody TAB 250 (Triton, Alameda, CA) | IHC | complete membrane staining in ≥10% tumor cells | Neg | 76 | 2 “readers” for FISH; 1 “reader” for IHC Results using IHC reported elsewhere^5^ concordance: 85%
| | | | | Pos | 21 | 2 “readers” for FISH; 1 “reader” for IHC Results using IHC reported elsewhere^5^ concordance: 85%
| | | | | Neg | 79

5 Results of TAM*HER2 measured using IHC and definitions of clinical responses were published in Elledge RM, Green S, Ciocca D et al. Clin Cancer Res 1998;4:7–12. (Note: longer duration of response required by Arpino et al. 2004)

Table IIIb-D Outcome Assessment

Study | Primary Outcomes | Secondary Outcomes | Criteria for Tumor Response or Progression | Independent Response Assessor? | F/U Frequency/Duration
Neoadjuvant Hormonal Therapy
None
Adjuvant Hormonal Therapy
Ryden et al 2005 | Recurrence free survival | None | Not reported | Not mentioned | Median for pts with no breast cancer event=14 yrs (range: 0–17 yrs). F/U annually for 5 yrs then every 18 mos.
Knoop et al. 2001 | Disease free survival | None | not reported | not mentioned | Not reported; but 10 year DFS included in tables.
Metastatic Hormonal Therapy
Arpino et al. 2004 | Response | Time to failure and overall survival | response = cCR or cPR or cSD cCR: no evidence of disease for ≥6 mos.^2^ cPR: ≥50% ↓ in cross-sectional area of all measurable lesions^2^ cSD: <cPR but not cPD^2^ cPD: ≥25% ↑ in cross-sectional area of all measurable lesions or appearance of new lesions^2^ | not mentioned | “Nearly all” tumor blocks >10 years old and some >20 years old. F/U frequency and duration not reported

Table IIIb-E Time to Event Outcomes

Study | Time to Event Outcomes
Neoadjuvant Hormonal Therapy
None
Adjuvant Hormonal Therapy
Ryden et al 2005 ER+ pts | Outcome | Grp | N | Med (mos) | 5 yr | 10yr | 15 yr | Test | p | HR (95%CI) | | Comments
Ryden et al 2005 ER+ pts | RFS | HER2+ | (IHC3+)
Ryden et al 2005 ER+ pts | | Tx | 8 | | ~0.7 | ~0.7 | ~0.7 | LR | 0.2 | 0.38 (0.08–1.79) | | No stat diff in RFS between HER2+ and HER2- pts (measured by IHC or FISH) among untreated pts. VEGFR2 status was predictive of TAM efficacy.
Ryden et al 2005 ER+ pts | | Cx | 13 | | ~0.4 | ~0.4 | ~0.4
Ryden et al 2005 ER+ pts | RFS | HER2- | (IHC 0–2+)
Ryden et al 2005 ER+ pts | | Tx | 115 | | ~0.75 | ~0.7 | ~0.65 | LR | 0.07 | 0.69(0.46–1.03)
Ryden et al 2005 ER+ pts | | Cx | 124 | | ~0.7 | ~0.6 | ~0.55
Ryden et al 2005 ER+ pts | RFS | HER2+ | (FISH)
Ryden et al 2005 ER+ pts | | Tx | | | Data not reported | | | LR | 0.14 | 0.21 (0.03–1.67)
Ryden et al 2005 ER+ pts | | Cx | | | Data not reported
Ryden et al 2005 ER+ pts | RFS | HER2- | (FISH)
Ryden et al 2005 ER+ pts | | Tx | | | Data not reported | | | LR | 0.14 | 0.73(0.47–1.12)
| Cx | | | Data not repoted
Knoop et al. 2001 (univariate) Tam=Tx; Obs=Cx | Outcome [underlined: DFS:] | Grp | N | Med (mos) | 1 yr | 2yr | 3yr | 4 yr | 5 yr | 10yr | Test | p | HR (95%CI) | Comments
Knoop et al. 2001 (univariate) Tam=Tx; Obs=Cx | HER2 - | Tx | | | | | | | 57(2) | 34(2) | LR | .0001 | | Bonferroni p=.0006
Knoop et al. 2001 (univariate) Tam=Tx; Obs=Cx | Or low + (n=1005) | Cx | | | | | | | 43(2) | 26(2)
Knoop et al. 2001 (univariate) Tam=Tx; Obs=Cx
Knoop et al. 2001 (univariate) Tam=Tx; Obs=Cx | Her 2 hi + (n=52) | Tx | | | | | | | 63(11) | 37(12) | LR | .5 | | Bonferroni p=.5
Knoop et al. 2001 (univariate) Tam=Tx; Obs=Cx | | Cx | | | | | | | 41(9) | 35(8)
Knoop et al. 2001 (univariate) Tam=Tx; Obs=Cx | | | | | | | | Cox | HER2+ (n=54): RR Tam vs Cx=0.89 (95%CI:0.63–1.27) HER2- (n=998): RR Tam vs Cx=0.86 (95%CI:0.78–0.93)
| | | | | | | MV Cox | HER2 and HER2TAM: Not significant (p Values not reported)
Metastatic Hormonal Therapy
Arpino et al. 2004 | Outcome | Grp | N | Med (mos) | 1 yr | 2yr | 3yr | 4 yr | 5 yr | 10yr | Test | p | HR (95%CI) | Comments
Arpino et al. 2004 | TTF | HER2- | 104 | 7 | ~.35 | ~.18 | ~.08 | ~.08 | 0 | 0 | LR | .007 | | HER2+ pts had lower median ER levels, even when all pts ER+
Arpino et al. 2004 | | HER2+ | 32 | 5 | ~.20 | ~.03 | No line | No line | No line
Arpino et al. 2004 | OS | HER2- | 104 | 31 | ~.85 | ~.60 | ~.50 | ~.25 | ~.20 | ~.05 | LR | .07
Arpino et al. 2004 | | HER2+ | 32 | 25 | ~.90 | ~.52 | ~.30 | ~.20 | ~.08 | ~.05
Arpino et al. 2004 | HER2+ as predictor of TTF | | | | | | | | | | MV Cox | 0.54 | 1.15 | adjusted
HER2+ as predictor of survival | | | | | | | | | | MV Cox | 0.97 | 0.99 | adjusted

NOTE: Analysis limited to steroid receptor positive pts. Standard error is in parentheses. LR=log-rank test of differences in DFS probabilities for pats with the variables in question when treated with tam or not.

Table IIIb-F Time to Event Outcome Regression Modeling

Study | Design/Outcome/Model | Candidate Predictors/Method for Identifying Candidates | Univariate Results, Variable (p value) | Selected Predictors/Methods for Selecting Predictors for Multivariate Model | Proportional Hazards Assumption Assessed?/Interactions Considered? | Multivariate Model Results, Variable (p value) | | Discrimination/Validation Methods/Results | Calibration/Goodness of Fit
Neoadjuvant Hormonal Therapy
None
Adjuvant Hormonal Therapy
Ryden et al 2005 | Cox | Not reported | ER+/HER2-(IHC) P=0.07 ER+/HER2+(IHC) P=0.2 ER+/PR+/HER2-(IHC), P=0.03 ER+/PR+/HER2+ (IHC), p=0.03 | Not certain; prob Age, tumor size, Node status, NHG, HER2 status, TAM, TAM*HER2. Analyzed ER+ and ER+/PR+ tumors Separately. | Not reported | ER+: TAM*HER2(IHC) p=0.4 ER+/PR+ TAM*HER2(IHC) p=0.3 | | Not reported | Not reported
Knoop et al. 2001 (among steroid receptor positive pts) | Cox | | Tam vs Cx for HR+ Within HER2+ and - subgroups RR HER2+=0.89 (95% CI: 0.63–1.27) RR HER2-=0.86 (95% CI: 0.78–0.93) | Tumor size, proportion node pos, histologic grade, p53 status, HER2 status, EGFR status, tamoxifen, and interactions betw. TAM and p53, EGFR, And HER2 | Interactions included | HER2 and HER2*TAM not significant | | Not reported | Not reported
Metastatic Hormonal Therapy
Arpino et al. 2004 | Cox* single-arm retrospective; TTF & OS | signif predictors of TTF in SWOG 8228, HER 1, HER 2 | | menopausal status, disease-free interval, ER and PR levels; HER1, HER2 | | TTF | | Not reported | Not reported
Arpino et al. 2004 | Cox* single-arm retrospective; TTF & OS | signif predictors of TTF in SWOG 8228, HER 1, HER 2 | | menopausal status, disease-free interval, ER and PR levels; HER1, HER2 | | HR | 1.15 | Not reported | Not reported
Arpino et al. 2004 | Cox* single-arm retrospective; TTF & OS | signif predictors of TTF in SWOG 8228, HER 1, HER 2 | | menopausal status, disease-free interval, ER and PR levels; HER1, HER2 | | p | .54 | Not reported | Not reported
Arpino et al. 2004 | Cox* single-arm retrospective; TTF & OS | signif predictors of TTF in SWOG 8228, HER 1, HER 2 | | menopausal status, disease-free interval, ER and PR levels; HER1, HER2 | | OS | | Not reported | Not reported
Arpino et al. 2004 | Cox* single-arm retrospective; TTF & OS | signif predictors of TTF in SWOG 8228, HER 1, HER 2 | | menopausal status, disease-free interval, ER and PR levels; HER1, HER2 | | HR | .99 | Not reported | Not reported
P | .97

* partially non-parametric

Table IIIb-G Tumor Response and Quality of Life

Study | Tumor Response | | | | | | | | Quality of Life
Neoadjuvant Hormonal Therapy
None
Adjuvant Hormonal Therapy
Ryden et al 2005 | Not reported | | | | | | | | Not reported
Knoop et al. 2001 | not reported | | | | | | | | not reported
Metastatic Hormonal Therapy
Arpino et al. 2004 | Grp | N | cCR+cPR+cSD | PD | NE | Test | p | Comments | not reported
Arpino et al. 2004 | HER2- | 104 | 56% | 44% | | χ^2^ | NS | | not reported
HER2+ | 32 | 47% | 53%

Table IIIb-H Response Regression Modeling

Study | Design/Outcome/Model | Candidate Predictors/Method for Identifying Candidates | Univariate Results, Variable (p value) | Selected Predictors/Methods for Selecting Predictors for Multivariate Model | Interactions Considered? | Multivariate Model Results, Variable (p value) | Discrimination/Validation Methods/Results | Calibration/Goodness of Fit
Neoadjuvant Hormonal Therapy
None
Adjuvant Hormonal Therapy
Ryden et al 2005 | not done or reported
Knoop et al. 2001 | not done or reported
Metastatic Hormonal Therapy
Arpino et al. 2004 | not done or reported

DSS=disease-specific survival; OS=overall survival; prop haz=proportional hazard

Data Abstraction Table

Table IIIb-I Adverse Events

Toxicity Type | Study | Severity or Grade | Results
Hormonal Therapy
Treatment-related mortality | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Nausea | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Vomiting | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Anorexia | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Lethargy | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Neurosensory | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Hearing loss | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Cardiac ischemia | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Diminished LVEF | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Arrhythmias | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Bronchopulmonary | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Dermatologic | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Kidney | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Anemia | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Thrombocytopenia | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Leukopenia or neutropenia | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Infection | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Other | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Treatment-related mortality | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Nausea | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Vomiting | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Anorexia | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Lethargy | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Neurosensory | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Hearing loss | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Cardiac ischemia | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Diminished LVEF | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Arrhythmias | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Bronchopulmonary | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Dermatologic | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Kidney | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Anemia | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Thrombocytopenia | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Leukopenia or neutropenia | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Infection | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Other | | | F/U (mo) | Grp1 n | % | Grp2 n | %

Table IIIb-J Randomized Trial Study Quality Ratings

Study | Initial Assembly of Comparable Groups | Low Loss to Followup, Maintenance of Comparable Groups | Measurements Reliable, Valid, Equal | Interventions Comparable/Clearly Defined | Appropriate Analysis of Results | Overall Rating | Funding/Sponsorship Source Acknowledged

Table IIIb-K Case Series/Single Arm Trial Study Quality Ratings

Study | Clearly Defined Question | Well-Described Study Population | Well-Described Intervention | Use of Validated Outcome Measures (Independently Assessed) | Appropriate Statistical Analysis | Well-Described Results | Discussion/Conclusions Supported by Data | Funding/Sponsorship Source Acknowledged
Hormonal Therapy
Chemotherapy

COMMENTS:

13310, Knoop et al. 2001 | “Strong precautions have to be taken when the predictive value of HER2 is analyzed in ER-positive patients because of the inverse correlation between HER2 and ER (p. 3381)...Unfortunately, this large study does not have enough statistical power to finally confirm of disconfirm whether a small group of steroid receptor positive patients is resistant to or have a detrimental response to tamoxifen treatment (p. 3383).”

Data Abstraction Table

Table IV-A Design, Enrollment and Treatment

Study | Design | Therapeutic Setting | n, Enrolled (Randomized) | n, Evaluated | n, Withdrawn (Lost to F/U) | Treatment Regimen (Agents)
Gasparini et al. 2007, Italy, multicenter; 12/00 – 09/04 | PII RCT | untreated MBC, t-IHC 2+/3+ (1^st^-line metastatic disease) | 124 enrolled (61 grp 1, 63 grp 2); allocation concealment: A | 123 for efficacy and toxicity, 118 for ORR | 1 for efficacy and toxicity, 6 for ORR | Grp 1: paclitaxel; Grp 2: paclitaxel + trastuzumab
Im et al. 2005, Korea, multicenter | PII, single-arm | MBC no previous CHT for metastatic disease (1^st^-line) | 40 | 39 for toxicity, 38 for response | 1 for toxicity, 2 for response (refused further tx) | Epirubicin + docetaxel
Fornier et al. 2005, USA, 1 center | RET analysis of PII | MBC, HER2 overexpressing and non-overexpressing | 55 of 95 in trial who had 1° tumor tested for tHER2 | 55 | | Paclitaxel + trastuzumab
Muller et al. 2004, Germany, multicenter | RCT | 1^st^-line tx for MBC | 103 of 597 in trial | 101 | 2 | Grp1: epirubicin + paclitaxel (ET, n=47, 62% sHER2+);Grp2: epirubicin + cyclophosphamide (EC, 54, 65% n=sHER2+)
Luftner et al. 2004, Germany, 1 center | PII | stage IV BC, 1 or 2 prev CHT (1 anthracycline-based) | 35 | 35 | | Dose-intensified paclitaxel (1^st^-line 6%, 2^nd^-line 60%, 3^rd^-line 34%)
Sandri et al. 2004, Italy, 1 center | Clinical trial | stage IV BC, ≥ 1 prev CHT for met dis (2^nd^-line+) | 64 | 39 | 25 | Cyclophosphamide + methotrexate
Colomer et al. 2004, Spain, 7 centers | PII | progressive advanced BC, no 1° tx for mets (1^st^-line) | 43 | 43 for toxicity 42 for efficacy | 1 | Paclitaxel + gemcitabine
Burstein et al. 2003, US, 17 centers | PII | stage IV BC, IHC HER2 3+ or FISH+, no prev CHT for met dis (1^st^-line) | 55 | 54 (43 had sHER2 values at baseline and after 1 tx cycle) | 1 (did not receive protocol-based tx) | Trastuzumab + vinorelbine
Lipton et al. 2003, mulitnational, multicenter | RCT | postmenopausal locally advanced, (stage IIIB) loco-regionally recurrent BC, MBC, ER+/PR? and/or PR+/ER? (1^st^-line) | 562 of 907 allocation concealment: B | 562 | | Grp1: letrozole (n=283) Grp2: tamoxifen (n=279)
Esteva et al. 2002, US, 1 center | PRO CS | MBC overexpressing tHER2, w/ or w/o previous tx for met dis, but no prior trastuzumab | 30 | 30 | | Trastuzumab + docataxel
Colomer et al. 2000, Spain, 1 center | PRO CS | MBC, no previous CHT for met dis (1^st^-line) | 77 | 55 | 3 | Doxorubicin+ paclitaxel
Colomer et al. 2006, Spain, 6 centers | PII | advanced BC (1^st^-line) | 52 | 47 | | IV vinorelbine+ IV gemcitabine
Yamauchi et al. 1997, US, ? centers | RCT | MBC (1^st^-line) | 94 of 369 | 94 | | 3 doses of droloxifene

Table IV-B Patient Characteristics

Study | Age/Menopausal Status | | | Race (%) | | | Disease Stage | | | Disease Staqe | | | Performance Status | | | Comorbidities or Other Prognostic Factors
Gasparini et al. 2007 | | Grp1 | Grp2 | | Grp1 | Grp2 | | Grp1 | Grp2 | | Grp1 | Grp2 | Scale | Grp1 | Grp2 | | Grp1 | 3rp2
Gasparini et al. 2007 | mn | | | B | | | I | | | # met sites | | | ECOG | | | E-/P- | 31.7 | 49.2
Gasparini et al. 2007 | md | 54.27 | 56.02 | W | | | IIa | | | 1 | 33.4 | 39.7 | 0 | 81.7 | 80.9 | E+/P+ | 36.7 | 36.5
Gasparini et al. 2007 | rng | 30–71 | 32–72 | H | | | IIb | | | 2 | 40.0 | 33.3 | 1 | 13.4 | 12.8 | E+/P- | 16.7 | 4.8
Gasparini et al. 2007 | sd | | | A | | | IIIa | | | 3 | 13.3 | 14.3 | 2 | 4.9 | 6.3 | E-/P+- | 10.0 | 4.8
Gasparini et al. 2007 | | | | O | | | IIIb | | | 4 | 8.3 | 7.9 | | | | E+/P? | 1.7
Gasparini et al. 2007 | pre | 31.7 | 33.2 | | | | IV | | | >4 | 5.0 | 4.8 | | | | ?? | 3.3 | 4.8
post | 68.3 | 66.8
Im et al. 2005 | | Grp1 | | | Grp1 | | | Grp1 | | | Grp1 | | Scale | Grp1
Im et al. 2005 | mn | | | B | | | I | | | # involved organs | | | ECOG
Im et al. 2005 | md | 49 | | W | | | IIa | | | 1 | 43.6 | | 0 | 20.5
Im et al. 2005 | rng | 35–70 | | H | | | IIb | | | 2 | 30.8 | | 1 | 53.8
Im et al. 2005 | sd | | | A | | | IIIa | | | ≥3 | 25.6 | | 2 | 25.6
Im et al. 2005 | | | | O | | | IIIb
Im et al. 2005 | pre | 41.0 | | | | | IV | 100
post | 58.9
Fornier et al. 2005 | | Grp1 | | | Grp1 | | | Grp1 | | | Grp1 | | KPS | Grp1
Fornier et al. 2005 | mn | | | B | | | I | | | # met sites | | | md | 90
Fornier et al. 2005 | md | 51 | | W | | | IIa | | | md | 2 | | rng | 70–100
Fornier et al. 2005 | rng | 33–67 | | H | | | IIb | | | rng | 1–4
Fornier et al. 2005 | sd | | | A | | | IIIa
Fornier et al. 2005 | | | | O | | | IIIb
Fornier et al. 2005 | pre | | | | | | IV | 100
post
Muller et al. 2004 | | Grp1+2 | | | Grp1+2 | | | Grp1+2 | | | Grp1+2 | | Scale | Grp1+2 | | | Grp1+2
Muller et al. 2004 | mn | | | B | | | I | | | visc | 80 | | | | | E+ | 61
Muller et al. 2004 | md | 56 | | W | | | Ila | | | dis
Muller et al. 2004 | rng | 33–73 | | H | | | IIb
Muller et al. 2004 | sd | | | A | | | IIIa
Muller et al. 2004 | | | | O | | | IIIb
Muller et al. 2004 | pre | | | | | | IV | 100
post
Luftner et al. 2004 | | Grp1 | | | Grp1 | | | Grp1 | | | Grp1 | | Scale | Grp1 | | | Grp1
Luftner et al. 2004 | mn | 48 | | B | | | I | | | # involved organs | | | | | | E+/P+ | 34%
Luftner et al. 2004 | md | | | W | | | IIa | | | 1 | 26 | | | | | E-&P- | 17
Luftner et al. 2004 | rng | 31–63 | | H | | | IIb | | | 2 | 31 | | | | | ? | 49
Luftner et al. 2004 | sd | | | A | | | IIIa | | | >2 | 43
Luftner et al. 2004 | | | | O | | | IIIb
Luftner et al. 2004 | pre | 9 | | | | | IV | 100
post | 91
7280, Sandri et al. 2004 | | Grp1 | | | Grp1 | | | Grp1 | | | Grp1 | | Scale | Grp1 | | | Grp1
7280, Sandri et al. 2004 | mn | 56 | | B | | | I | | | # involved organs
7280, Sandri et al. 2004 | md | | | W | | | IIa | | | 1 | 25.6
7280, Sandri et al. 2004 | rng | 36–81 | | H | | | IIb | | | 2 | 38.6
7280, Sandri et al. 2004 | sd | 11 | | A | | | IIIa | | | ≥3 | 35.8
7280, Sandri et al. 2004 | | | | O | | | IIIb
7280, Sandri et al. 2004 | pre | | | | | | IV | 100
post
7960, Colomer et al. 2004 | | Grp1 | | | Grp1 | | | Grp1 | | | Grp1 | | Scale | Grp1 | | | Grp1
7960, Colomer et al. 2004 | mn | | | B | | | I | | | # met sites | | | | | | E+ | 49
7960, Colomer et al. 2004 | md | 53 | | W | | | IIa | | | md | 3 | | md | 100 | | E- | 28
7960, Colomer et al. 2004 | rng | 29–72 | | H | | | IIb | | | rng | 1–6 | | rng | 70–100 | | ? | 23
7960, Colomer et al. 2004 | sd | | | A | | | IIIa
7960, Colomer et al. 2004 | | | | O | | | IIIb
7960, Colomer et al. 2004 | pre | | | | | | IV | 100
post
9100, Burstein et al. 2003 | | Grp1 | | | Grp1 | | | Grp1 | | | Grp1 | | Scale | Grp1 | | | Grp1
9100, Burstein et al. 2003 | mn | | | B | | | I | | | # met sites | | | ECOG | | | E+P+ | 37
9100, Burstein et al. 2003 | md | 54.5 | | W | | | IIa | | | md | 3 | | 0 | 70 | | E+/P- | 11
9100, Burstein et al. 2003 | rng | 29–82 | | H | | | IIb | | | rng | 1–6 | | 1 | 28 | | E-/P+ | 7
9100, Burstein et al. 2003 | sd | | | A | | | IIIa | | | | | | 2 | 2 | | E-/P- | 44
9100, Burstein et al. 2003 | | | | O | | | IIIb
9100, Burstein et al. 2003 | pre | | | | | | IV | 100
post
9520, Lipton et al. 2003 | | Grp1 | Grp2 | | Grp1 | Grp2 | | Grp1 | Grp2 | | Grp1 | Grp2 | Scale | Grp1 | Grp2 | | Grp1 | Grp2
9520, Lipton et al. 2003 | mn | | | B | | | I | 12 | 13 | # met sites | | | KPS | | | E+&P+ | 38 | 40
9520, Lipton et al. 2003 | md | 65 | 63 | W | 95 | 97 | Iia | 22 | 18 | 1 | 53 | 55 | md | 90 | 90 | E+/P+ | 28 | 27
9520, Lipton et al. 2003 | rng | 42–94 | 31–90 | H | | | Iib | 13 | 15 | 2 | 37 | 34 | rng | 50- | 50- | E?/P? | 34 | 33
9520, Lipton et al. 2003 | sd | | | A | | | IIIa | 7 | 6 | 3 | 10 | 11 | | 100 | 100
9520, Lipton et al. 2003 | | | | O | | | IIIb | 8 | 12
9520, Lipton et al. 2003 | pre | | | | | | IV | 30 | 28
post | | | | | | ? | 7 | 8
Esteva et al. 2002 | | Grp1 | | | Grp1 | | | Grp1 | | | Grp1 | | Scale | Grp1 | | | Grp1
Esteva et al. 2002 | mn | | | B | | | I | | | # met sites | | | KPS(%)
Esteva et al. 2002 | md | 45 | | W | | | IIa | | | 1 | 16 | | 90 | 63
Esteva et al. 2002 | rng | 33–78 | | H | | | IIb | | | 2 | 40 | | 80 | 20
Esteva et al. 2002 | sd | | | A | | | IIIa | | | 3 | 16 | | 70 | 16
Esteva et al. 2002 | | | | O | | | IIIb | | | ≥4 | 26
Esteva et al. 2002 | pre | | | | | | IV | 100
post
Colomer et al. 2000 | | Grp1 | | | Grp1 | | | Grp1 | | | Grp1 | | Scale | Grp1 | | | Grp1
Colomer et al. 2000 | mn | | | B | | | I | | | # met sites | | | | | | E+ | 66.7
Colomer et al. 2000 | md | | | W | | | IIa | | | 1 | 55.2 | | | | | E- | 33.3
Colomer et al. 2000 | rng | | | H | | | IIb | | | ≥2 | 44.8
Colomer et al. 2000 | sd | | | A | | | IIIa
Colomer et al. 2000 | | | | O | | | IIIb
Colomer et al. 2000 | pre | 34.5 | | | | | IV | 100
post | 65.5
Colomer et al. 2006 | | Grp1 | | | Grp1 | | | Grp1 | | | Grp1 | | Scale | Grp1 | | | Grp1
Colomer et al. 2006 | mn | | | B | | | I | | | # met sites | | | ECOG | | | E+ | 67.3
Colomer et al. 2006 | md | 64 | | W | | | IIa | | | md | 2 | | 0 | 41.2 | | E- | 32.7
Colomer et al. 2006 | rng | 34–81 | | H | | | IIb | | | rng | 1–4 | | 1 | 47.1
Colomer et al. 2006 | sd | | | A | | | IIIa | | | | | | 2 | 11.8
Colomer et al. 2006 | | | | O | | | IIIb
Colomer et al. 2006 | pre | | | | | | IV | 100
post
Yamauchi et al. 1997 | | Grp1+2+3 | | | Grp1+2+3 | | | Grp1+2+3 | | | Grp1+2+3 | | Scale | Grp1+2+3 | | | Grp1+2+3
Yamauchi et al. 1997 | <64 | 46.8 | | B | | | I | | | # met sites | | | | | | E++ | 26.7
Yamauchi et al. 1997 | ≥64 | 53.2 | | W | | | IIa | | | 1 | 44.7 | | | | | E+ | 28.7
Yamauchi et al. 1997 | | | | H | | | IIb | | | 2 | 37.2 | | | | | P++ | 20.2
Yamauchi et al. 1997 | pre | | | A | | | IIIa | | | ≥3 | 18.1 | | | | | P+ | 13.8
Yamauchi et al. 1997 | post | | | O | | | IIIb
| | | | | | IV | 100

Table IV-C HER2 Measurement Methods

Study | Assays (Name) | | Criteria for Positivity | | Test Results (%) | | Comments
Gasparini et al. 2007 | Serum: | Bayer ADVIA Centaur, at baseline | Serum | > 15 ng/ml | Pos | | No info on % SHER2+/-
Gasparini et al. 2007 | | | | | Equiv
Gasparini et al. 2007 | FISH | | FISH | | Neg
Gasparini et al. 2007 | | | | | Pos
Gasparini et al. 2007 | | | | | Equiv
Gasparini et al. 2007 | IHC: | HercepTest | IHC | 3+ | Neg
Gasparini et al. 2007 | | | | 2+ | Pos | 68.3
Gasparini et al. 2007 | | | | | Equiv | 31.7
| | | | Neg
Im et al. 2005 | Serum: | Oncogene ELISA | Serum | ≥ 15 | Pos | 14.8 | sHER2 tested in 27 of 40
Im et al. 2005 | | | | | Equiv
Im et al. 2005 | | | | | Neg | 85.2
Im et al. 2005 | FISH | | FISH | | Pos
Im et al. 2005 | | | | | Equiv
Im et al. 2005 | | | | | Neg
Im et al. 2005 | IHC: | Biogenix CB11 Ab | IHC | ≥ 10% tumor cells with intense membrane staining | Pos
Im et al. 2005 | | | | | Equiv
| | | | Neg
Fornier et al. 2005 | Serum: | Bayer Immuno 1 | Serum | >15 | Pos | 69
Fornier et al. 2005 | | | | | Equiv
Fornier et al. 2005 | | | | | Neg | 31
Fornier et al. 2005 | FISH | PathVysion (in 44 of 55) | FISH | ≥ 2 | Pos | 41
Fornier et al. 2005 | | | | | Equiv
Fornier et al. 2005 | | | | | Neg | 59
Fornier et al. 2005 | IHC: | HercepTest/CB11 | IHC | 2+/3+, Hercep Test | Pos | 47
Fornier et al. 2005 | | | | | Equiv
Fornier et al. 2005 | | | | | Neg | 53
Fornier et al. 2005 | | | | 2+/3+, CB11 | Pos | 36
Fornier et al. 2005 | | | | | Equiv
| | | | Neg | 64
Muller et al. 2004 | Serum: | Oncogene Science ELISA | Serum | ≥ 15 | Pos | 37
Muller et al. 2004 | | | | | Equiv
Muller et al. 2004 | | | | | Neg | 63
Muller et al. 2004 | FISH | | FISH | | Pos
Muller et al. 2004 | | | | | Equiv
Muller et al. 2004 | | | | | Neg
Muller et al. 2004 | IHC: | CB11 | IHC | 3+ | Pos | 31 | tHER2 tested in 29 of 103
Muller et al. 2004 | | | | | Equiv
| | | | Neg | 69
Luftner et al. 2004 | Serum: | Oncogene Science | Serum | ≥ 15 | Pos | 63
Luftner et al. 2004 | | | | | Equiv
Luftner et al. 2004 | | | | | Neg | 37
Luftner et al. 2004 | FISH | | FISH | | Pos
Luftner et al. 2004 | | | | | Equiv
Luftner et al. 2004 | | | | | Neg
Luftner et al. 2004 | IHC: | | IHC | | Pos
Luftner et al. 2004 | | | | | Equiv
| | | | Neg
Sandri et al. 2004 | Serum: | Bayer Immuno 1 | Serum | ≥ 15 | Pos | ?
Sandri et al. 2004 | | | | | Equiv
Sandri et al. 2004 | | | | | Neg | ?
Sandri et al. 2004 | FISH | | FISH | | Pos
Sandri et al. 2004 | | | | | Equiv
Sandri et al. 2004 | | | | | Neg
Sandri et al. 2004 | IHC: | Dako HercepTest | IHC | > 10% cancer cells with intense to moderate staining | Pos | 35 | tHER2 tested in 20 of 39
Sandri et al. 2004 | | | | | Equiv
| | | | Neg | 65
Colomer et al. 2004 | Serum: | Oncogene ELISA | Serum | ≥ 30 ng/ml | Pos | 29.3
Colomer et al. 2004 | | | | | Equiv
Colomer et al. 2004 | | | | | Neg | 70.7
Colomer et al. 2004 | FISH | | FISH | | Pos
Colomer et al. 2004 | | | | | Equiv
Colomer et al. 2004 | | | | | Neg
Colomer et al. 2004 | IHC: | | IHC | | Pos
Colomer et al. 2004 | | | | | Equiv
| | | | Neg
Burstein et al. 2003 | Serum: | Oncogene Science | Serum | | Pos | ?
Burstein et al. 2003 | | | | | Equiv
Burstein et al. 2003 | | | | | Neg | ?
Burstein et al. 2003 | FISH | ? | FISH | | Pos | 18
Burstein et al. 2003 | | | | | Equiv
Burstein et al. 2003 | | | | | Neg
Burstein et al. 2003 | IHC: | ? | IHC | 3+ | Pos | 80
Burstein et al. 2003 | | | | | Equiv | 2
| | | | Neg
Lipton et al. 2003 | Serum: | Immuno 1 assay | Serum | ≥ 15 | Pos | 29.2
Lipton et al. 2003 | | | | | Equiv
Lipton et al. 2003 | FISH | | FISH | | Neg | 70.8
Lipton et al. 2003 | | | | | Pos
Lipton et al. 2003 | | | | | Equiv
Lipton et al. 2003 | | | | - | Neg
Lipton et al. 2003 | IHC: | | IHC | | Pos
Lipton et al. 2003 | | | | | Equiv
| | | | Neg
Esteva et al. 2002 | Serum: | Immuno 1 | Serum | ≥ 15 | Pos | 70
Esteva et al. 2002 | | | | | Equiv
Esteva et al. 2002 | FISH | PathVysion | FISH | + | Neg | 30 | FISH done in 28 of 30
Esteva et al. 2002 | | | | | Pos | 85.7
Esteva et al. 2002 | | | | | Equiv
Esteva et al. 2002 | | | | | Neg | 14.3
Esteva et al. 2002 | IHC: | Neomarkers mAb e2-4001 | IHC | 3+ | Pos | 79.2 | IHC done in 24 of 30
Esteva et al. 2002 | | | | | Equiv
| | | 0–2+ | Neg | 20.8
Colomer et al. 2000 | Serum: | Calbiochem ELISA | Serum | 450 fmol/ml | Pos | 43.6 | sHER2 done in 55 of 58
Colomer et al. 2000 | | | | | Equiv
Colomer et al. 2000 | | | | | Neg | 56.4
Colomer et al. 2000 | FISH | | FISH | | Pos
Colomer et al. 2000 | | | | | Equiv
Colomer et al. 2000 | | | | | Neg
Colomer et al. 2000 | IHC: | CB11 | IHC | | Pos | 27.5 | IHC done in 40 of 58
Colomer et al. 2000 | | | | | Equiv
| | | | Neg | 72.5
Colomer et al. 2006 | Serum: | Oncogene Science ELISA | Serum | >30 | Pos | 29.8
Colomer et al. 2006 | | | | | Equiv
Colomer et al. 2006 | | | | | Neg | 70.2
Colomer et al. 2006 | FISH | | FISH | | Pos
Colomer et al. 2006 | | | | | Equiv
Colomer et al. 2006 | | | | | Neg
Colomer et al. 2006 | IHC: | | IHC | | Pos
Colomer et al. 2006 | | | | | Equiv
| | | | Neg
Yamauchi et al. 1997 | Serum: | Oncogene Science ELISA | Serum | ≥ 5000 U/ml | Pos | 34
Yamauchi et al. 1997 | | | | | Equiv
Yamauchi et al. 1997 | | | | | Neg | 66
Yamauchi et al. 1997 | FISH | | FISH | | Pos
Yamauchi et al. 1997 | | | | | Equiv
Yamauchi et al. 1997 | | | | | Neg
Yamauchi et al. 1997 | IHC: | | IHC | | Pos
Yamauchi et al. 1997 | | | | | Equiv
| | | | Neg

Table IV-D Outcome Assessment

Study | Primary Outcomes | Secondary Outcomes | Response Criteria | Independent Response Assessor | F/U Frequency/Duration
Gasparini et al. 2007 | ORR | Safety profile, TTP, duration of response | WHO | NR | Med: 16.6 mo
Im et al. 2005 | Response | Response duration (RD), TTP, overall survival, toxicity | WHO | NR | Med 22.5 mo
Fornier et al. 2005 | Correlation between sHER2 and tHER2 | Response | CR=disappearance; PR=>50%↓, ≥ 4 wks; MR=25–49%↓; SD=<25%↓; PD=≥25%↑ | NR | ≥ 4 wk
Muller et al. 2004 | OS | ORR, PFS | UICC | NR | Med 8.9 mo (0.5–36)
Luftner et al. 2004 | ORR | PFS, duration of response | Internationally accepted criteria (Miller et al. 1981) | NR | ≥ 4 wk
Sandri et al. 2004 | Clinical benefit (PR+SD) | TTP, OS | WHO | NR | 2 mo
Colomer et al. 2004 | Toxicity, response | Response, TTP | WHO | NR | 26 mo
Burstein et al. 2003 | ORR | Toxicity, TTF | RECIST | NR | 8 wk
Lipton et al. 2003 | TTP | ORR, CB | IUAC | NR | 3 mo
Esteva et al. 2002 | Response | Toxicity | ECOG | NR | ≥ 8 wk
Colomer et al. 2000 | Response | Response duration | WHO | Yes | med 23 mo
Colomer et al. 2006 | ORR | Toxicity, PFS | WHO | NR | ?
Yamauchi et al. 1997 | Response | TTP, OS | ? | NR | ?

Table IV-E Time to Event Outcomes

Study | Time to Event Outcomes
Gasparini et al. 2007
Im et al. 2005 | Outcome | Grp | N | Med (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | Test | p | HR (95%CI)
Im et al. 2005 | TTP | sHER2+ | 4 | 2.8 | | | | | | LR | <0.001
Im et al. 2005 | | sHER2- | 19 | 8.3
Im et al. 2005 | RD | sHER2+ | 3 | 1.5 | 0 | | | | | LR | <0.001
Im et al. 2005 | | sHER2- | 13 | 6.7 | ~43 | ~33
Im et al. 2005 | OS | sHER2+ | 4 | 12.4 | ~50 | ~26 | | | | LR | 0.076
| sHER2- | 23 | not reached | ~72 | ~56
Fornier et al. 2005
Muller et al. 2004 | Outcome | Grp | N | Med (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | Test | p | HR (95%CI) | Comments
Muller et al. 2004 | OS | sHER2+/EC | 19 | ~8.4 | ~50 | ~15 | ~0 | | | LR | 0.092
Muller et al. 2004 | | sHER2-/EC | 35 | ~22 | ~77 | ~40 | ~15
Muller et al. 2004 | | sHER2+/ET | 18 | ~16 | ~60 | ~10 | ~0 | | | LR | NS
Muller et al. 2004 | | sHER2-/ET | 29 | ~14 | ~65 | ~10 | ~0
Muller et al. 2004 | PFS | sHER2-/EC | 35 | ~7 | ~30 | ~0 | ~0 | | | LR | NS
Muller et al. 2004 | | sHER2-/ET | 29 | ~9 | ~21 | ~0 | ~0
Muller et al. 2004 | | sHER2+/EC | 19 | ~12 | ~21 | ~0 | ~0 | | | LR | 0.0341
| sHER2+/ET | 18 | ~9 | ~28 | ~0 | ~0
Luftner et al. 2004 | Outcome | Grp | N | Mn (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | Test | p | HR (95%CI)
Luftner et al. 2004 | Resp Dur | sHER2+ | 9 | 6.0 | ~0 | | | | | LR | 0.042
Luftner et al. 2004 | | sHER2- | 5 | 2 | ~60
Luftner et al. 2004 | PFS | sHER2+ | 22 | 3 | ~3 | | | | | LR | 0.098
| sHER2- | 13 | 4 | ~10
Sandri et al. 2004 | Outcome | Grp | N | Mn (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | Test | p | HR (95%CI) | Comments
Sandri et al. 2004 | TTP | sHER2+ | ? | 2 | ~0 | ~0 | ~0 | | | LR | 0.007
Sandri et al. 2004 | | sHER2- | ? | 11 | ~34 | ~12 | ~7
Sandri et al. 2004 | OS | sHER2+ | ? | 11 | ~47 | ~0 | ~0 | | | LR | <0.001
| sHER2- | ? | 16 | ~84 | ~49 | ~42
Colomer et al. 2004 | Outcome | Grp | N | Med (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | Test | p | HR (95%CI) | Comments
Colomer et al. 2004 | Resp Dur | sHER2+ | 5 | 7.9 | ~40 | ~0 | | | | LR | 0.04
| sHER2- | 24 | 14.4 | ~55 | ~37
Burstein et al. 2003 | Outcome | Grp | N | Med (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | Test | p | HR (95%CI) | Comments
9520, Lipton et al. 2003 | Outcome | Grp | N | Med (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | Test | p | HR (95%CI) | Comments
9520, Lipton et al. 2003 | TTP | sHER2+ | 164
9520, Lipton et al. 2003 | | letrazole | 87 | 6.1 | ~28 | ~7 | ~6 | ~4 | | Cox | 0.0596 | 0.73 (0.53,1.01)
9520, Lipton et al. 2003 | | tamoxiven | 77 | 3.3 | ~17 | ~5 | ~3
9520, Lipton et al. 2003 | | sHER2- | 398
9520, Lipton et al. 2003 | | letrazole | 196 | 12.2 | ~53 | ~29 | ~20 | ~14 | | Cox | 0.0019 | 0.70 (0.56,0.88)
9520, Lipton et al. 2003 | | tamoxiven | 202 | 8.5 | ~38 | ~20 | ~10 | ~8
9520, Lipton et al. 2003 | TTF | sHER2+ | 164
9520, Lipton et al. 2003 | | letrazole | 87 | 6.0 | | | | | | Cox | 0.0418
9520, Lipton et al. 2003 | | tamoxiven | 77 | 3.2
9520, Lipton et al. 2003 | | sHER2- | 398
9520, Lipton et al. 2003 | | letrazole | 196 | 11.6 | | | | | | Cox | 0.0066
| tamoxiven | 202 | 6.2
11880, Esteva et al. 2002 | Outcome | Grp | N | Med (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | Test | p | HR (95%CI) | Comments
14870, Colomer et al. 2000 | Outcome | Grp | N | Med (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | Test | p | HR (95%CI) | Comments
14870, Colomer et al. 2000 | Resp Dur | sHER2+ | 15 | 7.5 | ~26 | | | | | LR | 0.035
| sHER2- | 24 | 11 | ~50 | ~35 | | | | MV Cox | 0.06
22050, Colomer et al. 2006 | Outcome | Grp | N | Med (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | Test | p | HR (95%CI) | Comments
26670, Yamauchi et al. 1997 | Outcome | Grp | N | Med (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | Test | p | HR (95%CI) | Comments
26670, Yamauchi et al. 1997 | TTP | sHER2+ | 32 | ~3 | ~13 | ~13 | | | | Cox | 0.0003 | 0.36 (0.21, 0.63) adjusted
26670, Yamauchi et al. 1997 | | sHER2- | 62 | ~8 | ~43 | ~28
26670, Yamauchi et al. 1997 | OS | sHER2+ | 32 | ~28 | ~74 | ~54 | | | | Cox | 0.003 | 0.35 (0.17, 0.70) adjusted
| sHER2- | 62 | | ~92 | ~63

Table IV-F Time to Event Outcome Regression Modeling

Study | Design/Outcome/Model | Candidate Predictors/Method for Identifying Candidates | Univariate Results, Variable (p value) | Selected Predictors/Methods for Selecting Predictors for Multivariate Model | Proportional Hazards Assumption Assessed?/Interactions Considered? | Multivariate Model Results, Variable (p value) | Discrimination/Validation Methods/Results | Calibration/Goodness of Fit
Gasparini et al. 2007 | PII RCT | unclear | NR | treatment arm, subgroup defined by each clinical or biomarker variable | PH assumption NR; pre-selected 1^st^-order interactions investigated | interactions: | NR | NR
Gasparini et al. 2007 | TTP | | | | | tHER2 (0.0938)
Gasparini et al. 2007 | Cox PH | | | | | sHER2+ (0.0538)
Gasparini et al. 2007 | | | | | | non-visc (0.7845)
Gasparini et al. 2007 | | | | | | E+/P+ (0.7845)
Gasparini et al. 2007 | | | | | | #lesions (0.7355)
Gasparini et al. 2007 | | | | | | ECOGPS (0.4643)
Gasparini et al. 2007 | | | | | | EGFR (0.9607)
Gasparini et al. 2007 | | | | | | CA 15.3 (0.1209)
Gasparini et al. 2007 | | | | | | tHER2Δ (0.2684)
Gasparini et al. 2007 | | | | | | EGFRΔ (0.1984)
| | | | | CA15.3Δ (0.0666)
Im et al. 2005
Fornier et al. 2005
Muller et al. 2004
Luftner et al. 2004
Sandri et al. 2004
Colomer et al. 2004
Burstein et al. 2003
Lipton et al. 2003 | RCT | treatment effects Within sHER2 sub-Groups | NA | sHER2 subgroups | PHA? | subgroup analyses (see Table 4E) | NR | NR
Lipton et al. 2003 | TTP,
Lipton et al. 2003 | TTF
Cox PH
Esteva et al. 2002
Colomer et al. 2000 | PRO | NR | menop (0.74) | selection methods | PHA? | menop (0.81) | NR | NR
Colomer et al. 2000 | CS, | | relapse (0.83) | NR | | relapse (0.95)
Colomer et al. 2000 | Resp dur, | | adjCHT (0.85) | | | adjCHT (0.64)
Colomer et al. 2000 | Cox PH | | #mets (0.53) | | | #mets (0.37)
Colomer et al. 2000 | | | CA15-3 (0.03) | | | CA15-3 (0.21)
| | sHER2 (0.03) | | | sHER2 (0.04)
Colomer et al. 2006
Yamauchi et al. 1997 | RCT | age | NR | stepwise | PHA?/ | TTP: | NR | NR
Yamauchi et al. 1997 | TTP, OS | dom dis site | | | no | sHER2 (0.0003)
Yamauchi et al. 1997 | Cox PH | sHER2 | | | | P++ (0.02)
Yamauchi et al. 1997 | | time to recurr | | | | OS:
Yamauchi et al. 1997 | | E receptor | | | | sHER2 (0.003)
Yamauchi et al. 1997 | | P receptor | | | | P++ (0.002)
| # met site | | | | DF > 5yr (0.01)

Table IV-G Tumor Response and Quality of Life

Study | Tumor Response (%) | | | | | | | | | | Quality of Life
Gasparini et al. 2007 | Grp | N | CR | PR | SD | PD | | Test | p | Comments | Scale | Domain | F/U | Grp | n | mn±sd
Im et al. 2005 | Grp | N | CR | PR | SD | PD | | Test | p | Comments
Im et al. 2005 | sHER2+ | 4 | 0 | 75 | 25 | | | ChiSq | 0.45
sHER2- | 23 | 13.0 | 43.4 | 26.1 | 17.4
Fornier et al. 2005 | Grp | N | Response | No response | | | | Test | p | Comments
Fornier et al. 2005 | sHER2 | | | | | | | | | Response=CR+PR
Fornier et al. 2005 | + | 38 | 50 | | 50 | | | FE | 1.0
Fornier et al. 2005 | - | 17 | 47 | | 43
Fornier et al. 2005 | Δ<15 | 25 | 68 | | 32 | | | FE | 0.005
Fornier et al. 2005 | Δ≥15 | 13 | 15 | | 85
Fornier et al. 2005 | Δ≥55% | 25 | 68 | | 32 | | | FE | 0.015 | OR 4.25
Fornier et al. 2005 | Δ<55% | 30 | 33 | | 67 | | | | | 95% CI:
| | | | | | | | | 1.37–13.19
Muller et al. 2004 | Grp | N | CR+PR | | SD | PD | | Test | p | Comments
Muller et al. 2004 | sHER2+/ET | 18 | 50.0 | | 33.3 | 16.7 | | ChiSq | NS
Muller et al. 2004 | sHER2-/ET | 26 | 46.2 | | 38.5 | 15.4
Muller et al. 2004 | sHER2+/EC | 17 | 29.4 | | 35.3 | 35.3 | | ChiSq | 0.059
sHER2-/EC | 31 | 41.9 | | 35.5 | 22.6
Luftner et al. 2004 | Grp | N | CR+PR | | SD | PD | | Test | p | Comments
Luftner et al. 2004 | sHER2+ | 22 | 40.9 | | 36.4 | 22.7 | | MH | 0.40 | mn dur 25.7 wks
sHER2- | 19 | 38.5 | | 30.8 | 30.8 | | | | mn dur 65.2 wks (p=0.042)
Sandri et al. 2004 | Grp | N | CR | PR | SD | PD | NE | Test | p | Comments
Colomer et al. 2004 | Grp | N | Response | No response | | | | Test | p | Comments
Colomer et al. 2004 | sHER2+ | 15 | 42 | 58 | | | | FE | 0.02
sHER2- | 26 | 83 | 17
Burstein et al. 2003 | Grp | N | No progression | | | ProgressIon | | | | Comments
Burstein et al. 2003 | sHER2+ | ? | | | | | | | | AU ROC=0.8947
sHER2- | ? | | | | | | | | BL or Δ in sHER2 do not not predict response, but no ↓ in sHER2 predicted progression
Lipton et al. 2003 | Grp | N | CR+PR | | SD+PD | | | Test | p | Comments
Lipton et al. 2003 | sHER2+ | 164
Lipton et al. 2003 | letrazole | | 17 | | 83 | | | log regr | 0.4507
Lipton et al. 2003 | tamoxifen | | 13 | | 87
Lipton et al. 2003 | sHER2- | 398
Lipton et al. 2003 | letrazole | | 39 | | 61 | | | log regr | 0.0078
Lipton et al. 2003 | tamoxifen | | 26 | | 74
Lipton et al. 2003 | Grp | N | CR+PR+SD | | | PD | | Test | p | Comments
Lipton et al. 2003 | sHER2+ | 164
Lipton et al. 2003 | letrazole | | 33 | | | 67 | | log regr | 0.3057
Lipton et al. 2003 | tamoxifen | | 26 | | | 74
Lipton et al. 2003 | sHER2- | 398
Lipton et al. 2003 | letrazole | | 57 | | | 43 | | log regr | 0.0162
tamoxifen | | 45 | | | 55
Esteva et al. 2002 *Relevant to both Q4 and Q3 | Grp | N | CR+PR | | SD+PD | | | Test | p | Comments
Esteva et al. 2002 *Relevant to both Q4 and Q3 | sHER2+ | 21 | 76 | | 24 | | | FE | 0.04
Esteva et al. 2002 *Relevant to both Q4 and Q3 | sHER2- | 9 | 33 | | 67
Esteva et al. 2002 *Relevant to both Q4 and Q3 | IHC 3+ | 19 | 63 | | 37 | | | FE | 0.99
Esteva et al. 2002 *Relevant to both Q4 and Q3 | IHC 0–2+ | 5 | 60 | | 40
Esteva et al. 2002 *Relevant to both Q4 and Q3 | FISH+ | 24 | 67 | | 33 | | | FE | 0.60
FISH- | 4 | 50 | | 50
Colomer et al. 2000 *Relevant to both Q4 and Q3 | Grp | N | CR | PR | No response | | | Test | p | Comments
Colomer et al. 2000 *Relevant to both Q4 and Q3 | sHER2+ | 24 | 0 | 62 | 37 | | | Chi sq | 0.021
Colomer et al. 2000 *Relevant to both Q4 and Q3 | sHER2- | 31 | 26 | 52 | 23
Colomer et al. 2000 *Relevant to both Q4 and Q3 | IHC+ | 11 | 9 | 55 | 36 | | | Chi sq | 0.219
IHC- | 28 | 18 | 64 | 18
Colomer et al. 2006 | Grp | N | CR+PR | | No response | | | Test | p | Comments
Colomer et al. 2006 | sHER2+ | 14 | 50 | | 50 | | | ? | 0.9
sHER2- | 33 | 48.5 | | 51.5
Yamauchi et al. 1997 | Grp | N | Response | | No response | | | Test | p | Comments
Yamauchi et al. 1997 | sHER2+ | 32 | 9 | | 91 | | | FE | 0.00001
sHER2- | 62 | 56 | | 44

Table IV-H Response Regression Modeling

Study | Design/Outcome/Model | Candidate Predictors/Method for Identifying Candidates | Univariate Results, Variable (p value) | Selected Predictors/Methods for Selecting Predictors for Multivariate Model | Interactions Considered? | Multivariate Model Results, Variable (p value) | Discrimination/Validation Methods/Results | Calibration/Goodness of Fit
Gasparini et al. 2007 | PII RCT ORR logistic | unclear | NR | treatment arm, subgroup defined by each clinical or biomarker variable | preselected 1^st^-order interactions investigated | interactions: tHER2 (0.0035) sHER2+ (0.6044 non-visc (0.8639) E+/P+ (0.3079) #lesions (0.0669) ECOGPS (0.1688) EGFR (0.5996) CA 15.3 (0.3415) tHER2Δ(0.983) EGFRΔ(0.8283) CA153Δ(0.6524) | NR | NR
Im et al. 2005
Fornier et al. 2005
Muller et al. 2004
Luftner et al. 2004
Sandri et al. 2004
Colomer et al. 2004
Burstein et al. 2003
Lipton et al. 2003 | RCT ORR, CB logistic | treatment effects within sHER2 subgroups | NA | sHER2 subgroups | yes | subgroup analyses (see Table 4G) | NR | NR
Esteva et al. 2002
Colomer et al. 2000 | PRO CS, ORR, logistic | NR | menop (0.39) relapse (0.79) adjCHT (0.91) #mets (0.32) CA15-3 (0.36) sHER2 (0.01) | selection methods NR | NA | menop (0.15) relapse (0.57) adjCHT (0.88) #mets (0.35) CA15-3 (0.83) sHER2 (0.03)
Colomer et al. 2006
Yamauchi et al. 1997 | RCT Response logistic | age dom dis site sHER2 time to recurr E receptor P receptor # met site | NR | stepwise | no | sHER2 (0.0001) no hx CHT (0.01) soft site (0.01) E++ (0.04) | NR | NR

Table IV-I Adverse Events

Toxicity Type | Study | Severity or Grade | Results
Treatment-related mortality | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Nausea | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Vomiting | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Anorexia | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Lethargy | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Neurosensory | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Hearing loss | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Cardiac ischemia | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Diminished LVEF | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Arrhythmias | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Bronchopulmonary | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Dermatologic | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Kidney | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Anemia | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Thrombocytopenia | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Leukopenia or neutropenia | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Infection | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Other | | | F/U (mo) | Grp1 n | % | Grp2 n | %

Table IV-J Randomized Trial Study Quality Ratings

Study | Initial Assembly of Comparable Groups | Low Loss to Followup, Maintenance of Comparable Groups | Measurements Reliable, Valid, Equal | Interventions Comparable/Clearly Defined | Appropriate Analysis of Results | Overall Rating | Funding/Sponsorship Source Acknowledged
Gasparini et al. 2007 | + | + | + | + | + | Good | Yes, industry funded
Muller et al. 2004 | ? | ? | + | + | + | ? | -
Lipton et al. 2003 | + | - | + | + | + | Fair | +
Yamauchi et al. 1997 | ? | ? | + | + | + | ? | +

Table IV-K Case Series/Single Arm Trial Study Quality Ratings

Study | Clearly Defined Question | Well-Described Study Population | Well-Described Intervention | Use of Validated Outcome Measures (Independently Assessed) | Appropriate Statistical Analysis | Well-Described Results | Discussion/Conclusions Supported by Data | Funding/Sponsorship Source Acknowledged
Im et al. 2005 | + | + | + | + (NA/-) | + | + | + | +
Fornier et al. 2005 | + | + | + | + (-) | + | + | + | +
Luftner et al. 2004 | + | + | + | + (-) | + | - (no AEs) | + | +
Sandri et al. 2004 | + | + | + | + (-) | + | - (no AEs) | + | +
Colomer et al. 2004 | + | + | + | + (-) | + | + | + | -
Burstein et al. 2003 | + | + | + | + (-) | + | + | + | +
Esteva et al. 2002 | + | + | + | + (-) | + | + | + | +
Colomer et al. 2000 | + | - | + | + (+) | + | - (no AEs) | + | +
Colomer et al. 2006 | + | + | + | + (-) | + | + | + | +

Data Abstraction Table

Table V-A Lung Cancer: Design, Enrollment and Treatment

Study | Design | Therapeutic Setting | n, Enrolled (Randomized) | n, Evaluated | n, Withdrawn (Lost to F/U) | Treatment Regimen (Agents)
Krug et al. 2005 | Phase 2 RCT | Untreated advanced (Stage 3b or 4) nonsmall cell without prior chemotherapy. Prior RT must have been completed 3 weeks prior to study entry | 64 | 64 (Grp1:31, Grp2:34) | | Docetaxel+trastuzumab (Grp1) or palitaxel+trastuzamab (Grp2)
Cappuzzo et al. 2005 | Prospective Clinical Trial | NSCLC with locally advanced or metastatic disease which progressed after chemotherapy/medical contraindications to chemotx | 102 | 101 | 1 | Gefitinib
Hirsch et al. 2005 | Prospective Clinical Trial | Stage IIIb or IV BAC or adeno with BAC features 1^st^ -line CHT (101) or 2^nd^+-line (36) | 145 | 56 | 89 | Gefitinib until progression or prohibitive toxicity
Pelosi et al. 2005 | RET CS | Stage I NSCLC with no (neo)adjuvant tx and stage I–III NET, treated | 345 (NSCLC 207 (NET) | Same (retrospective study) | 0 | No neoadjuvant tx for NSCLC. All pts had radical surgery+mediastinal LN dissection
Saad et al. 2004 | RET CS | Unselected patients with stage I conventional and bronchioloalveolar adenocarcinoma | 100 | 100 | 0 | complete surgical resection, no chemotherapy or radiotherapy
Langer et al. 2004 | PII | Recurrent, stage IV, or stage IIIB NSCLC, HercepTest 1+/2+/3+ | 56 | 53 | 3 | Trastuzumab, paclitaxel and carboplatin
Cappuzzo et al. 2003 | PRO CS | Stage IIIB/IV NSCLC, pretreated with 1^st^-line platinum-based CHT and RT | 63 | 63 | | 2^nd^+-line gefitinib
Koukourakis et al. 1999 | RET CS | Surgically treated NSCLC | 216 | 189 with survival data | 27 | Treated with surgery alone
Koukourakis et al. 2000 | RET CS | Operable NSCLC T1,2-N0,1 | 112 | 112 | 0 | Surgery alone without RT or Chemotx
Graziano et al. 1998 | PII | Stage IIIA lung cancer with ipsilateral mediastinal node involvement | 66 | 46 had pre-study IHC staining for Her-2. 1 additional case was not accounted for | 20 | Two cycles of cisplatin-etoposide then surgical resection ten two additional cycles of cisplatin-etoposide then radiation to the thorax
Pfeiffer et al. 1996 | RET CS | NSCLC treated surgically without adjuvant radiotx. Two pt had adjuvant cytotoxic tx | 186 | Same (RET CS) | 0 | Radical surgery (152) Macroscopic tissue was left in 34 pts

Table V-B Lung Cancer: Patient Characteristics

Study | Age | | | % Female | | Race (%) | | | Disease Stage | | | Performance Status | | | Comorbidities or Other Prognostic Factors
Krug et al. 2005 | | Grp1 | Grp2 | Grp1 | Grp2 | | Grp1 | Grp2 | | Grp1 | Grp2 | Scale | Grp1 | Grp2 | | Grp1 | Grp2
Krug et al. 2005 | mn | | | | | B | | | Ia | | | KPS | | | Bone Mets | 37 | 21
Krug et al. 2005 | md | | | 48 | 76 | W | | | Ib | | | 90% | 35 | 26 | Wt Loss>5% | 10 | 18
Krug et al. 2005 | rng | | | (p=0.03) | | H | | | IIa | | | 80% | 52 | 62
Krug et al. 2005 | sd | | | Her-2+ | Her-2- | A | | | IIb | | | 70% | 13 | 12 | | Her2+ | Her2-
Krug et al. 2005 | | | | | | O | | | IIIa | | | | | | Bone Mets ((p=0.77) | 30 | 27
Krug et al. 2005 | | | | 65% | 62% | | | | IIIb | 10% | 18% | | Her2+ | Her2- | Wt Loss>5% (p=0.12) | 25 | 9
Krug et al. 2005 | | | | | | | | | IV | 90% | 82% | 70% | 30 | 2
Krug et al. 2005 | | | | | | | | | LD | | | (p=0.02)
Krug et al. 2005 | | | | | | | | | ED
Krug et al. 2005 | | | | | | | | | | Her2+ | Her2-
Krug et al. 2005 | | | | | | | | | Iiib | 10 | 16
| | | | | | | | IV | 90 | 84
Cappuzzo et al. 2005 | | Grp1 | | Grp1 | | | Grp1 | | | Grp1 | | Scale | Grp1 | | Smoking | Grp1 | Grp2
Cappuzzo et al. 2005 | mn | | | | | B | | | Ia
Cappuzzo et al. 2005 | md | | | | | W | | | Ib
Cappuzzo et al. 2005 | rng | | | | | H | | | IIa
Cappuzzo et al. 2005 | sd | | | | | A | | | IIb
Cappuzzo et al. 2005 | | | | | | O | | | IIIa
Cappuzzo et al. 2005 | | | | | | | | | IIIb
Cappuzzo et al. 2005 | | | | | | | | | IV
Cappuzzo et al. 2005 | | | | | | | | | LD
| | | | | | | | ED
Hirsch et al. 2005 | | All pt | | All pt | | | All pt | | | All PT | | Scale | All pt | | Smoking
Hirsch et al. 2005 | mn | | | 51% | | B | | | Ia | | | SWOG
Hirsch et al. 2005 | md | 68 | | | | W | | | Ib | | | 0 | 89%
Hirsch et al. 2005 | rng | 34–88 | | | | H | | | IIa | | | 1/2 | 11%
Hirsch et al. 2005 | sd | | | | | A | | | IIb
Hirsch et al. 2005 | | | | | | O | | | IIIa
Hirsch et al. 2005 | | | | | | | | | IIIb | 11%
Hirsch et al. 2005 | | | | | | | | | IV | 89%
Hirsch et al. 2005 | | | | | | | | | LD
| | | | | | | | ED
Pelosi et al. 2005 | | NSCLC | NET | | | | Grp1 | | | NSCLC | | Scale | Grp1 | | Smoking | Grp1 | Grp2
Pelosi et al. 2005 | male | | | NCLC | NET | B | | | Ia | 43 | | | | | Information was available but not recorded
Pelosi et al. 2005 | | | | | | W | | | Ib | 57
Pelosi et al. 2005 | mn | 63.4 | 58.7 | 11.0% | 37.2% | H | | | IIa
Pelosi et al. 2005 | md | 64 | 63 | | | A | | | IIb
Pelosi et al. 2005 | rng | 35,82 | 16,80 | | | O | | | IIIa
Pelosi et al. 2005 | sd | 8.1 | 14.4 | | | | | | IIIb
Pelosi et al. 2005 | female | | | | | | | | IV
Pelosi et al. 2005 | mn | 61.6 | 52.6 | | | | | | LD
Pelosi et al. 2005 | md | 62 | 54 | | | | | | ED
Pelosi et al. 2005 | rng | 41,80 | 15,75 | | | | | | | NET
Pelosi et al. 2005 | sd | 8.8 | 15.4 | | | | | | pIa | 47
Pelosi et al. 2005 | | | | | | | | | pIb | 18
Pelosi et al. 2005 | | | | | | | | | pIIa | 9.7
Pelosi et al. 2005 | | | | | | | | | pIIb | 8.2
Pelosi et al. 2005 | | | | | | | | | pIIIa | 15.5
| | | | | | | | pIIIb | <1
Saad et al. 2004 | | Grp1 | Grp2 | Grp1 | Grp2 | | Grp1 | Grp2 | | Grp1 | Grp2 | Scale | Grp1 | Grp2 | Smoking | Grp1 | Grp2
Saad et al. 2004 | mn | 64 | 67 | 38 | 46 | B | | | Ia | 46 | 68
Saad et al. 2004 | md | | | | | W | | | Ib | 54 | 32
Saad et al. 2004 | rng | | | | | H | | | IIa
Saad et al. 2004 | sd | 11 | 7 | | | A | | | IIb
Saad et al. 2004 | | | | | | O | | | IIIa
Saad et al. 2004 | | | | | | | | | IIIb
Saad et al. 2004 | | | | | | | | | IV
Saad et al. 2004 | | | | | | | | | LD
| | | | | | | | ED
Langer et al. 2004 | | Grp1 | | Grp1 | | | Grp1 | | | Grp1 | | Scale | | Grp1 | Smoking | Grp1 | Grp2
Langer et al. 2004 | mn | | | 49.1 | | B | 3.8 | | Ia | | | ECOG
Langer et al. 2004 | md | 59 | | | | W | 92.4 | | Ib | | | 0 | 52.8
Langer et al. 2004 | rng | 31–77 | | | | H | | | IIa | | | 1 | 47.2
Langer et al. 2004 | sd | | | | | A | | | IIb
Langer et al. 2004 | | | | | | O | 3.8 | | IIIa
Langer et al. 2004 | | | | | | | | | IIIb | 9.4
Langer et al. 2004 | | | | | | | | | IV | 81.2
| | | | | | | | Rec | 9.4
Cappuzzo et al. 2003 | | Grp1 | | Grp1 | | | Grp1 | | | Grp1 | | Scale | Grp1 | | Smoking | Grp1 | Grp2
Cappuzzo et al. 2003 | mn | 58.5 | | 36.5 | | B | | | Ia | | | ECOG
Cappuzzo et al. 2003 | md | | | | | W | | | Ib | | | 0 | 25
Cappuzzo et al. 2003 | rng | 31–79 | | | | H | | | IIa | | | 1 | 64
Cappuzzo et al. 2003 | sd | | | | | A | | | IIb | | | 2 | 11
Cappuzzo et al. 2003 | | | | | | O | | | IIIa
Cappuzzo et al. 2003 | | | | | | | | | IIIb | 17.5
Cappuzzo et al. 2003 | | | | | | | | | IV | 82.5
Cappuzzo et al. 2003 | | | | | | | | | LD
| | | | | | | | ED
Koukourakis et al. 1999 | | Grp1 | | Grp1 | | | Grp1 | | | Grp1 | | Scale | Grp1 | | Smoking | Grp1 | Grp2
Koukourakis et al. 1999 | mn | | | | | B | | | T1 | 29.2
Koukourakis et al. 1999 | md | | | | | W | | | T2 | 70.8
Koukourakis et al. 1999 | rng | | | 16.7 | | H | | | N0 | 56.5
Koukourakis et al. 1999 | sd | | | | | A | | | N1 | 43.5
Koukourakis et al. 1999 | <60 | 25.5% | | | | O | | | Grad | e
Koukourakis et al. 1999 | >60 | 74.5% | | | | | | | 1,2 | 47.2
| | | | | | | | 3 | 52.8
Koukourakis et al. 2000 | | Grp1 | | Grp1 | | | Grp1 | | | Grp1 | | Scale | Grp1 | | Smoking | Grp1 | Grp2
Koukourakis et al. 2000 | mn | | | | | B | | | T1 | 37
Koukourakis et al. 2000 | md | 63 | | | | W | | | T2 | 63
Koukourakis et al. 2000 | rng | 45–76 | | | | H | | | N0 | 62.5
Koukourakis et al. 2000 | sd | | | 20.5 | | A | | | N1 | 37.5
| | | | | O
Graziano et al. 1998 | | Grp1 | | Grp1 | | | Grp1 | | | Grp1 | | Scale | Grp1 | | Smoking | Grp1 | Grp2
Graziano et al. 1998 | mn | | | | | B | | | Ia
Graziano et al. 1998 | md | | | | | W | | | Ib
Graziano et al. 1998 | rng | | | | | H | | | IIa
Graziano et al. 1998 | sd | | | | | A | | | IIb
Graziano et al. 1998 | | | | | | O | | | IIIa | 100
Graziano et al. 1998 | | | | | | | | | IIIb
Graziano et al. 1998 | | | | | | | | | IV
Graziano et al. 1998 | | | | | | | | | LD
| | | | | | | | ED
Pfeiffer et al. 1996 | | Grp1 | | Grp1 | | | Grp1 | | | Grp1 | | Scale | Grp1 | | Smoking | Grp1 | Grp2
Pfeiffer et al. 1996 | mn | | | 29.6% (55/186) | | B | | | Ia | 46.2
Pfeiffer et al. 1996 | md | 61 | | | | W | | | II | 25.8
Pfeiffer et al. 1996 | rng | 42–79 | | | | H | | | IIIa | 22.0
Pfeiffer et al. 1996 | sd | | | | | A | | | IIIb | 1.6
Pfeiffer et al. 1996 | | | | | | O | | | IV | 4.3
Pfeiffer et al. 1996 | | | | | | | | | LD
| | | | | | | | ED

Table V-C Lung Cancer: HER2 Measurement Methods

Study | Assays (Name) | | Criteria for Positivity | | Test Results (%) | | Comments
Krug et al. 2005 | Serum: | | Serum | | Pos
Krug et al. 2005 | | | | | Equiv
Krug et al. 2005 | | | | | Neg
Krug et al. 2005 | FISH | standard fashion at Albany Medical Center | FISH | | Pos
Krug et al. 2005 | | | | | Equiv
Krug et al. 2005 | | | | | Neg
Krug et al. 2005 | | | IHC | 2–3+ | Pos | 20/64 (31%)
Krug et al. 2005 | IHC: | HerceptTest (Dako) | | | Equiv
| | | 0–1+ | Neg | 44/64 (69%)
Cappuzzo et al. 2005 | Serum: | | Serum | | Pos
Cappuzzo et al. 2005 | | | | | Equiv
Cappuzzo et al. 2005 | | | | | Neg
Cappuzzo et al. 2005 | FISH | PathVysion Her-2 DNA probe kit (Vysis) | FISH | ≥ 4 copies ≥40% of cells | Pos | 23/101 (22.8%)
Cappuzzo et al. 2005 | | | | | Equiv
Cappuzzo et al. 2005 | | | | ≤ 4copies > 40% of cells | Neg | 78/101 (77.2%)
Cappuzzo et al. 2005 | | | IHC | score 200–400 | Pos | 5/72 (6.9%)
Cappuzzo et al. 2005 | IHC: | HerceptTest (Dako) | | | Equiv
| | | | Neg | 67/72 (93.1%)
Hirsch et al. 2005 | Serum: | | Serum | | Pos
Hirsch et al. 2005 | | | | | Equiv
Hirsch et al. 2005 | | | | | Neg
Hirsch et al. 2005 | FISH | PathVysion Her-2 DNA probe kit (Vysis) | FISH | ≥ 4 copies ≥ 40% cells | Pos | 17/56 (30%)
Hirsch et al. 2005 | | | | | Equiv
Hirsch et al. 2005 | | | | ≤ 4 copies >40% of cells | Neg | 39/56 (70%)
Hirsch et al. 2005 | IHC: | | IHC | | Pos
Hirsch et al. 2005 | | | | | Equiv
| | | | Neg
Pelosi et al. 2005 | Serum: | | Serum | | Pos | NSCLC | NET
Pelosi et al. 2005 | | | | | Equiv
Pelosi et al. 2005 | | | | | Neg
Pelosi et al. 2005 | FISH: | PathVysion Her-2 DNA Probe kit (Vysis) | FISH | | Pos
Pelosi et al. 2005 | | | | | Neg
Pelosi et al. 2005 | | | IHC | (only if FISH+) | 2+3+ | 29/345 (8.4%) | 11/207 (5.3%)
Pelosi et al. 2005 | IHC: | rabbit polyclonal antiserum to HER2 (Dako, Envision plus-HRP) membrane only | | | 1+ | 28/345 (8.1%) | 0
Pelosi et al. 2005 | | | | | 0 | 288/345 (83.5%) | 196/207 (94.7%)
| | Only 5 cases had gene amplification and were IHC 2+/3+. These were the tumors used for the survival analysis
Saad et al. 2004 | Serum: | | Serum | | Pos
Saad et al. 2004 | | | | | Equiv
Saad et al. 2004 | | | | | Neg
Saad et al. 2004 | FISH | | FISH | | Pos
Saad et al. 2004 | | | | | Equiv
Saad et al. 2004 | | | | | Neg
Saad et al. 2004 | IHC: | rabbit polyclonal, Dako | IHC | complete/almost complete staining of entire cell periphery in > 10% | Pos | AC: 38, BAC: 18
Saad et al. 2004 | | | | complete/almost complete staining of entire cell periphery in > 10% | Equiv
| | | Neg
Langer et al. 2004 | Serum: | | Serum | | Pos
Langer et al. 2004 | | | | | Equiv
Langer et al. 2004 | | | | | Neg
Langer et al. 2004 | FISH | | FISH | | Pos
Langer et al. 2004 | | | | | Equiv
Langer et al. 2004 | | | | | Neg
Langer et al. 2004 | IHC: | Dako HercepTest | IHC | 1+ | Pos | 100
Langer et al. 2004 | | | | | Equiv
| | | | Neg
Cappuzzo et al. 2003 | Serum: | | Serum | | Pos
Cappuzzo et al. 2003 | | | | | Equiv
Cappuzzo et al. 2003 | | | | | Neg
Cappuzzo et al. 2003 | FISH | | FISH | | Pos
Cappuzzo et al. 2003 | | | | | Equiv
Cappuzzo et al. 2003 | | | | | Neg
Cappuzzo et al. 2003 | IHC: | Dako Herceptest | IHC | 2+ | Pos | 16.3
Cappuzzo et al. 2003 | | | | 3+ | | 18.6
Cappuzzo et al. 2003 | | | | | Equiv
| | | | Neg | 65.1
Koukourakis et al. 1999 | Serum: | | Serum | | Pos
Koukourakis et al. 1999 | | | | | Equiv
Koukourakis et al. 1999 | | | | | Neg
Koukourakis et al. 1999 | FISH | | FISH | | Pos
Koukourakis et al. 1999 | | | | | Equiv
Koukourakis et al. 1999 | | | | | Neg
Koukourakis et al. 1999 | IHC: | monoclonal antibody NCL-CB11(Novocastra Laboratories) | IHC | strong diffuse staining | Pos | 166 (76.9%)
Koukourakis et al. 1999 | | | | | Equiv
| | | negative/weak staiining | Neg | 50 (23.1%)
Koukourakis et al. 2000 | Serum: | | Serum | | Pos
Koukourakis et al. 2000 | | | | | Equiv
Koukourakis et al. 2000 | | | | | Neg
Koukourakis et al. 2000 | FISH | | FISH | | Pos
Koukourakis et al. 2000 | | | | | Equiv
Koukourakis et al. 2000 | | | | | Neg
Koukourakis et al. 2000 | IHC: | monoclonal antibody NCL-CB11(Novocastra Laboratories | IHC | strong (>70% cells) | Pos | 55 (49%) | membrane staining was not analyzed
Koukourakis et al. 2000 | | | | weak (25–70% cells) | Equiv | 31 (28%)
| | | less than 25% of cells | Neg | 26 (23%)
Graziano et al. 1998 | Serum: | | Serum | | Pos
Graziano et al. 1998 | | | | | Equiv
Graziano et al. 1998 | | | | | Neg
Graziano et al. 1998 | FISH | | FISH | | Pos
Graziano et al. 1998 | | | | | Equiv
Graziano et al. 1998 | | | | | Neg
Graziano et al. 1998 | IHC: | polyclonal rabbit HER-2 antiserum (DBW-2). | IHC | membrane or membrane and cytoplasmiic reactivity throughout the tissue section | Pos | 22% (10/46)
| | | Neg | 78% (36/46)
Pfeiffer et al. 1996 | Serum: | | Serum | | Pos
Pfeiffer et al. 1996 | | | | | Equiv
Pfeiffer et al. 1996 | | | | | Neg
Pfeiffer et al. 1996 | FISH | | FISH | | Pos
Pfeiffer et al. 1996 | | | | | Equiv
Pfeiffer et al. 1996 | | | | | Neg
Pfeiffer et al. 1996 | IHC: | A485 (Dako, Denmark) | IHC | >=80% | high | 26% (49)
Pfeiffer et al. 1996 | | | | <80% | low | 58% (108)
| | | 0 cells | Neg | 16% (29)

Table V-D Lung Cancer: Outcome Assessment

Study | Primary Outcomes | Secondary Outcomes | Response Criteria | Independent Response Assessor | F/U Frequency/Duration
Krug et al. 2005 | Response rate | OS | Standard bidimensional criteria for measurable disease or improvement for patients with evaluable disease | NR | 56 mo
Cappuzzo et al. 2005 | Objective respones | TTP | Response evaluation criteria in Solid Tumors Group Criteria | Yes | 2 mo
Hirsch et al. 2005 | Response and overall survival | | RECIST | NR | > 24 mo
Pelosi et al. 2005 | Prevalence and prognosis of FISH her-2 abnormalities in lung CA (both NET and NSCLC | OS, DFS | NR | NR | NET: 53.3 +/-53.6 months NSCLC: 72.6 +/-49.3 months
Saad et al. 2004 | OSOverall surval | | | | AC: 52 ± 20 mo; BAC: 40 ± 17 mo
Langer et al. 2004 | Toxicity | Response, OS, PFS | ? | NR | med 34 mo
Cappuzzo et al. 2003 | Response | TTP, OS | RECIST | NR | > 19 mo
Koukourakis et al. 1999 | OS | | NR | NR | med 42 mo (18–84)
Koukourakis et al. 2000 | OS | | NR | NR | med 46 mo (2–96)
Graziano et al. 1998 | Response, DFS, OS | | NR | NR
Pfeiffer et al. 1996 | OS | | | | 66 mos (40–119)

Table V-E Time to Event Outcomes

Study
Krug et al. 2005 | Outcome | Grp | N | Med (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | Test | p | HR (95%CI) | Comments IHC 2+/3+
Krug et al. 2005 | OS | IHC+ | 20 | 14.3 | ~65 | ~30 | ~20 | ~20 | | | NS | | Comments IHC 2+/3+
| IHC- | 45 | 14.9 | ~59 | ~33 | ~16 | ~10
Cappuzzo et al. 2005 | Outcome | Grp | N | Med (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | Test | p | HR (95%CI) | Comments discrepancies discrepancies
Cappuzzo et al. 2005 | OS | FISH+ | 23 | 20.8 | 60.9 | ~38 | | | | LR | 0.056 | | Comments discrepancies discrepancies
Cappuzzo et al. 2005 | | FISH- | 78 | 8.4 | 37.2 | ~15 | | | | | | | Comments discrepancies discrepancies
Cappuzzo et al. 2005 | TTP | FISH+ | 23 | 9.05 | 34.8 | | | | | LR | 0.02 | | Comments discrepancies discrepancies
| FISH- | 78 | 2.7 | 9.0 | ~5
Hirsch et al. 2005 | Outcome | Grp | N | Med (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | Test | p | HR (95%CI) | Comments Cox HER2 not entered
Hirsch et al. 2005 | OS | FISH+ | 17 | 16 | ~64 | ~26 | | | | LR | 0.80 | | Comments Cox HER2 not entered
| FISH- | 39 | 13 | ~61 | ~35
Pelosi et al. 2005 | Outcome | Grp | N | Med (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | Test | p | HR (95%CI) | Comments
Pelosi et al. 2005 | OS | FISH+ | 5 | > 14 yrs | 100 | ~80 | ~60 | ~60 | ~60 | LR | NS | | Comments
Pelosi et al. 2005 | | FISH- | 340 | > 14 yrs | 94 | ~88 | ~80 | ~72 | ~70 | | | | Comments
Pelosi et al. 2005 | DFS | FISH+ | 5 | > 14 yrs | ~80 | ~60 | ~60 | ~60 | ~60 | LR | NS | | Comments
| FISH- | 340 | ~13 yrs | ~86 | ~77 | ~74 | ~70 | ~65
Saad et al. 2004 | Outcome | Grp | N | Med (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | Test | p | HR (95%CI) | Comments Cox: HER2 independent Cox: HER2 independent
Saad et al. 2004 | OS | AC-IHC+ | 19 | ~24 | ~81 | ~50 | ~18 | ~0 | | ? | <0.001 | | Comments Cox: HER2 independent Cox: HER2 independent
Saad et al. 2004 | | AC-IHC- | 31 | ~43 | ~96 | ~75 | ~54 | ~41 | | | | | Comments Cox: HER2 independent Cox: HER2 independent
Saad et al. 2004 | | BAC-IHC+ | 9 | ~30 | ~91 | ~63 | ~27 | ~0 | ~0 | ? | <0.001 | | Comments Cox: HER2 independent Cox: HER2 independent
| BAC-IHC- | 41 | ~39 | ~100 | ~100 | ~50 | ~30 | ~19
Langer et al. 2004 | Outcome | Grp | N | Med (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | Test | p | HR (95%CI) | Comments
Langer et al. 2004 | OS | IHC3+ | 8 | 10.9 | 37.5 | 25 | | | | LR | 0.77 | | Comments
Langer et al. 2004 | | IHC2+ | 23 | 8.6 | 26.1 | 13.5 | | | | | | | Comments
Langer et al. 2004 | | IHC1+ | 22 | 14.3 | 59.1 | 11.4 | | | | | | | Comments
Langer et al. 2004 | PFS | IHC3+ | 8 | 2.7 | - | | | | | LR | 0.34 | | Comments
Langer et al. 2004 | | IHC2+ | 23 | 3.8 | ~9 | | | | | | | | Comments
| IHC1+ | 22 | 3.9 | ~6
Cappuzzo et al. 2003 | Outcome | Grp | N | Med (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | Test | p | HR (95%CI) | Comments
Cappuzzo et al. 2003 | TTP | IHC 2+/3+ | 15 | 3.5 | | | | | | LR | NS | | Comments
Cappuzzo et al. 2003 | | IHC 0 /1+ | 28 | 3.7 | | | | | | | | | Comments
Cappuzzo et al. 2003 | OS | IHC 2+/3+ | 15 | 5.7 | | | | | | LR | NS | | Comments
| IHC 0 /1+ | 28 | 6.8
Koukourakis et al. 1999 | Outcome | Grp | N | Med (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | Test | p | HR (95%CI) | Comments Cox HER2 not entered
Koukourakis et al. 1999 | OS | IHC+ | | | | | | | | LR | 0.51 | | Comments Cox HER2 not entered
| IHC-
Koukourakis et al. 2000 | Outcome | Grp | N | Med (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | Test | p | HR (95%CI) | Comments
Koukourakis et al. 2000 | OS | IHC+ | | | | | | | | | NS | | Comments
| IHC-
Graziano et al. 1998 | Outcome | Grp | N | Med (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | Test | p | HR (95%CI) | Comments
Graziano et al. 1998 | OS | IHC+ | 10 | 10.5 | | | | | | LR | 0.617 | | Comments
| IHC- | 37 | 17.5
Pfeiffer et al. 1996 | Outcome | Grp | N | Med (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | Test | p | HR (95%CI) | Comments
Pfeiffer et al. 1996 | OS | IHC-none | 29 | ~34 | ~75 | ~66 | ~42 | ~32 | ~20 | LR | NS | 0.89 (0.56–1.41) | Comments
Pfeiffer et al. 1996 | | IHC-low | 108 | ~24 | ~58 | ~50 | ~38 | ~33 | ~25 | | | | Comments
| IHC-high | 49 | ~24 | ~75 | ~50 | ~40 | ~30 | ~25

Table V-F Lung Cancer: Time to Event Outcome Regression Modeling

Study | Design/Outcome/Model | Candidate Predictors/Method for Identifying Candidates | Univariate Results, Variable (p value) | Selected Predictors/Methods for Selecting Predictors for Multivariate Model | Proportional Hazards Assumption Assessed?/Interactions Considered? | Multivariate Model Results, Variable (p value) | Discrimination/Validation Methods/Results | Calibration/Goodness of Fit
Krug et al. 2005
Cappuzzo et al. 2005
Hirsch et al. 2005
Pelosi et al. 2005
Saad et al. 2004 | RETCS OS CPHM | | signif: HER2 p53 VEGF | age, sex, recurrence, angiolymphatic invasion, HER2, p53, VEGF | | independent predictors: recurrence, angiolymphatic invasion, p53, HER2, VEGF
Langer et al. 2004
Cappuzzo et al. 2003
Koukourakis et al. 1999
Koukourakis et al. 2000
Graziano et al. 1998
Pfeiffer et al. 1996

Table V-G Lung Cancer: Tumor Response and Quality of Life

Study | Tumor Response (%) | | | | | | | | | Quality of Life
Krug et al. 2005 | Grp | N | CR | PR | SD | PD | Test | p | Comments | Scale | Domain | F/U | Grp | n | mn±sd
Cappuzzo et al. 2005 | Grp | N | CR+PR | | SD | PD | Test | p | Comments | Scale | Domain | F/U | Grp | n | mn±sd
Cappuzzo et al. 2005 | FISH+ | 23 | 34.8 | | | | ChiSq | 0.001
Cappuzzo et al. 2005 | FISH- | 78 | 6.4 | | | | | 0.08 | Cox MV adjusted for EGFR mutation HR 0.22 (95% CI: 0.04, 1.21)
Cappuzzo et al. 2005 | Grp | N | CR+PR+SD | | | PD | Test | p | Comments
Cappuzzo et al. 2005 | FISH+ | 23 | 56.5 | | | | ChiSq | 0.04
FISH- | 78 | 33.3
Hirsch et al. 2005 | Grp | N | CR+PR | | SD | PD | Test | p | Comments | Scale | Domain | F/U | Grp | n | mn±sd
Hirsch et al. 2005 | FISH+ | 11 | 36% | | | | ? | >.05
FISH- | 28 | 46%
Pelosi et al. 2005 | Grp | N | CR | PR | SD | PD | Test | p | Comments | Scale | Domain | F/U | Grp | n | mn±sd
Saad et al. 2004 | Grp | N | CR | PR | SD | PD | Test | p | Comments | Scale | Domain | F/U | Grp | n | mn±sd
Langer et al. 2004 | Grp | N | Response | | | | Test | p | Comments | Scale | Domain | F/U | Grp | n | mn±sd
Langer et al. 2004 | IHC3+ | 8 | 25
Langer et al. 2004 | IHC2+ | 23 | 17.4
IHC1+ | 21 | 33.3
Cappuzzo et al. 2003 | Grp | N | CR | PR | SD | PD | Test | p | Comments | Scale | Domain | F/U | Grp | n | mn±sd
Cappuzzo et al. 2003 | HER2 2+/3+ | 15 | | 13.3 | 26.7 | | ChiSq | 0.126
HER2 0/1+ | 28 | | 14.3 | 50.0
Koukourakis et al. 1999 | Grp | N | CR | PR | SD | PD | Test | p | Comments | Scale | Domain | F/U | Grp | n | mn±sd
Koukourakis et al. 2000 | Grp | N | CR | PR | SD | PD | Test | p | Comments | Scale | Domain | F/U | Grp | n | mn±sd
Graziano et al. 1998 | Grp | N | Response | | | | Test | p | Comments | Scale | Domain | F/U | Grp | n | mn±sd
Graziano et al. 1998 | HER2+ | 10 | 30 | | | | FE | 0.999
HER2- | 36 | 33
Pfeiffer et al. 1996 | Grp | N | CR | PR | SD | PD | Test | p | Comments | Scale | Domain | F/U | Grp | n | mn±sd

Table V Lung Cancer: Adverse Events

Toxicity Type | Study | Severity or Grade | Results
Treatment-related mortality | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Nausea | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Vomiting | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Anorexia | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Lethargy | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Neurosensory | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Hearing loss | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Cardiac ischemia | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Diminished LVEF | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Arrhythmias | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Bronchopulmonary | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Dermatologic | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Kidney | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Anemia | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Thrombocytopenia | | | F/U (mo) | Grp1 n 10% | % | Grp2 n 3% | %
Leukopenia or neutropenia | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Infection | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Other | | | F/U (mo) | Grp1 n | % | Grp2 n | %

Table V-J Lung Cancer: Randomized Trial Study Quality Ratings

Study | Initial Assembly of Comparable Groups | Low Loss to Followup, Maintenance of Comparable Groups | Measurements Reliable, Valid, Equal | Interventions Comparable/Clearly Defined | Appropriate Analysis of Results | Overall Rating | Funding/Sponsorship Source Acknowledged
Krug et al. 2005 | yes | No | yes | yes | yes | fair | yes

Table V-K Lung Cancer: Case Series/Single Arm Trial Study Quality Ratings

Study | Clearly Defined Question | Well-Described Study Population | Well-Described Intervention | Use of Validated Outcome Measures (Independently Assessed) | Appropriate Statistical Analysis | Well-Described Results | Discussion/Conclusions Supported by Data | Funding/Sponsorship Source Acknowledged
Cappuzzo et al. 2005 | + | - | + | + | + | + | + | +
Hirsch et al. 2005 | + | - | + | + | + | + | + | +
Pelosi et al. 2005 | + | +/- | + | + (?) | + | + | + | +
Saad et al. 2004 | + | + | + | + | + | + | + | -
Langer et al. 2004 | + | + | + | + (?) | + | + | + | +
Cappuzzo et al. 2003 | + | + | + | +(?) | - | + | + | -
Koukourakis et al. 1999 | + | - | + | + | + | - | + | +
Koukourakis et al. 2000 | + | - | + | + (?) | + | - | ? | +
Graziano et al. 1998 | + | - | + | + (?) | + | +/- | + | +
Pfeiffer et al. 1996 | + | - | + | + | + | +/- | + | -

Table V-L Ovarian Cancer. Design, Enrollment and Treatment

Study | Design | Therapeutic Setting | n, Enrolled (Randomized) | n, Evaluated | n, Withdrawn (Lost to F/U) | | Treatment Regimen (Agents)
Camilleri-Broet et al., 2004 | RCT | Histologically-proven advanced epithelial ovarian carcinoma | 164 | 117 | 47 | no histology slides | cisplatin + epirubicin + cyclophosphamide (2 different doses of cyclophosphamide combined)
Bookman et al., 2003 | PII, single-arm | recurrent or persistent epithelial ovarian or primary peritoneal carcinoma, tIHC 2+/3+ | 45 of 95 who had tIHC 2+/3+ | 41 | 2 | inadequate pathology or wrong primary tumor | trastuzumab
2 | did not receive tx
Bowman et al., 2002 | PII, single-arm | previously treated relapsed ovarian carcinoma | 60 | 50 | 9 | no CT evidence of disease | letrozole
1 | unsatisfactory baseline scan
Campos et al., 2001 | retrospective | previously treated relapsed and refractory ovarian carcinoma | 72 | 48 | 24 | blocks not available | liposomal doxorubicin
Hengstler et al., 1999 | retrospective | primary epithelial ovarian carcinoma | 77 | 77 | 0 | | carboplatin or cisplatin + cyclophosphamide
Di Leo et al., 1995 | PII, single-arm | previously treated relapsed and refractory stage III–IV epithelial ovarian carcinoma | 78 | 42 | 6 | deemed ineligible before study entry | mitoxantrone + ifosfamide
30 | tumor samples unavailable

Table V-M Ovarian Cancer. Patient Characteristics

Study | Age | | Race (%) | | Disease Stage | | | Performance Status | | Histologic Grade | | Histologic Type
Camilleri-Broet et al., 2004 | | Grp1 | | Grp1 | | Grp1 | | Scale | Grp1 | Tumor Grade | Grp1 | Tumor Type | Grp1
Camilleri-Broet et al., 2004 | mn | | B | | Ia | | | WHO | | 1 (well diff) | 0 | serous or mixed | 63
Camilleri-Broet et al., 2004 | md | 59 | W | | Ib | | | 0 | 27 | 2 (moderately diff w/out nuclear atypia) | 13 | epithelial
Camilleri-Broet et al., 2004 | rng | 23–70 | H | | IIa | | | 1 | 60 | 3 (moderately diff w/nuclear atypia) | 40 | clear cell | 3
Camilleri-Broet et al., 2004 | sd | | A | | IIb | | | 2 | 8 | 4 (poorly diff or undiff w/nuclear atypia) | 29 | endometrioid | 8
Camilleri-Broet et al., 2004 | | | O | | IIIa | 4 | | missing | 5 | missing | 18 | undiff carcinoma | 26
Camilleri-Broet et al., 2004 | | | | | IIIb | 25
Camilleri-Broet et al., 2004 | | | | | IIIc | 65
Camilleri-Broet et al., 2004 | | | | | IV | 22
| | | | (1 missing)
Bookman et al., 2003 | | Grp1 | | Grp1 | | Grp1 | | Scale | Grp1 | Tumor Grade | Grp1 | Tumor Type | Grp1
Bookman et al., 2003 | mn | | B | 4.9 | Ia | | | GOG | | 1 (well diff) | 2.4 | serous | 65.9
Bookman et al., 2003 | md | 59 | W | 92.7 | Ib | | | 0 | 61 | 2 (moderately diff) | 22.0 | clear cell | 17.1
Bookman et al., 2003 | rng | 44–82 | H | 2.4 | Iia | | | 1 | 39 | 3 (poorly diff) | 75.6 | endometrioid | 7.3
Bookman et al., 2003 | sd | | A | | Iib | | | | | | | other | 9.8
Bookman et al., 2003 | | | O | | IIIa | | | | | | | (2 mixed epithelial, 1 TCC, 1 undiff)
Bookman et al., 2003 | | | | | IIIb
| | | | IV
Bowman et al., 2002 | | Grp1 | | Grp1 | | Grp1 | | Scale | Grp1 | Tumor Grade | Grp1 | Tumor Type | Grp1
Bowman et al., 2002 | mn | | B | | Ia | | | WHO | 100 | well diff | 5 | serous | 72
Bowman et al., 2002 | md | 65 | W | | Ib | | | 0–2 | | moderately diff | 22 | endometrioid | 18
Bowman et al., 2002 | rng | 43–83 | H | | IIa | | | | | poorly diff | 65 | other (not defined) | 10
Bowman et al., 2002 | sd | | A | | IIb | | | | | not documented | 8
Bowman et al., 2002 | | | O | | IIIa
Bowman et al., 2002 | | | | | IIIb
| | | | IV
Campos et al., 2001 | | Grp1 | | Grp1 | | Grp1 | | Scale | Grp1 | Tumor Grade | Grp1 | Tumor Type | Grp1
Campos et al., 2001 | mn | | B | | Initial presentation | | | NR | | poorly diff | 58 | serous/papillary | 81
Campos et al., 2001 | md | 57 | W | | I/II | 6 | | 0 | 25 | | | endometrioid | 3
Campos et al., 2001 | rng | 31–77 | H | | III | 72 | | 1 | 28 | | | clear cell | 7
Campos et al., 2001 | sd | | A | | IV | 22 | | 2 | 18 | | | mixed | 7
Campos et al., 2001 | | | O | | | | | 3 | 3 | | | other (not defined) | 3
| | | | | | | Unk | 26
Hengstler et al., 1999 | | Grp1 | | Grp1 | | Grp1 | | Scale | Grp1 | Tumor Grade | Grp1 | Tumor Type | Grp1
Hengstler et al., 1999 | mn | | B | | Ia | FIGO | | | | WHO | | serous
Hengstler et al., 1999 | md | | W | | Ib | I + II | 20 | | | GI–GIII | | nonserous
Hengstler et al., 1999 | rng | | H | | IIa
Hengstler et al., 1999 | sd | | A | | IIb
Hengstler et al., 1999 | | | O | | IIIa | III+IV | 50
Hengstler et al., 1999 | | | | | IIIb
| | | | IV
Di Leo et al., 1995 | | Grp1 | | Grp1 | | Grp1 | | Scale | Grp1 | Tumor Grade | Grp1 | Tumor Type | Grp1
Di Leo et al., 1995 | mn | | B | | Ia | | | ECOG | | well diff | 15 | serous/papillary | 83
Di Leo et al., 1995 | md | 57 | W | | Ib | | | 0 | 40 | moderately diff | 28 | mucinous | 8
Di Leo et al., 1995 | rng | 39–74 | H | | IIa | | | 1 | 49 | poorly diff | 38 | endometrioid | 6
Di Leo et al., 1995 | sd | | A | | IIb | | | 2 | 11 | not documented | 19 | clear cell | 3
Di Leo et al., 1995 | | | O | | IIIa
Di Leo et al., 1995 | | | | | IIIb
| | | | IV

Table V-N Ovarian Cancer. HER2 Measurement Methods

Study | Assays (Name) | | Criteria for Positivity | | Test Results (%) | | Comments
Camilleri-Broet et al., 2004 | Serum | | Serum | | Pos
Camilleri-Broet et al., 2004 | | | | | Equiv
Camilleri-Broet et al., 2004 | | | | | Neg
Camilleri-Broet et al., 2004 | FISH | | FISH | | Pos
Camilleri-Broet et al., 2004 | | | | | Equiv
Camilleri-Broet et al., 2004 | | | | | Neg
Camilleri-Broet et al., 2004 | IHC | Novocastra Labs CB11 | IHC | plasma membranes of > 10% cells moderately or strongly labeled | Pos | 16 | 95 patients, variability observed within some tumors (not defined)
Camilleri-Broet et al., 2004 | | | | plasma membranes of > 10% cells moderately or strongly labeled | Equiv | ? | 95 patients, variability observed within some tumors (not defined)
| | | Neg | ?
Bookman et al., 2003 | Serum | Genentech ELISA | Serum | > 2.60 ng/ml | Pos | 33 | 24 of 41 pts had sHER2 data
Bookman et al., 2003 | | | | | Equiv
Bookman et al., 2003 | | | | | Neg | 67
Bookman et al., 2003 | FISH | | FISH | | Pos
Bookman et al., 2003 | | | | | Equiv
Bookman et al., 2003 | | | | | Neg
Bookman et al., 2003 | IHC | LabCorp 4D5 ± CB11 | IHC | 2+/3+ | Pos | 34
Bookman et al., 2003 | | | | | Equiv | 66
| | | | Neg
Bowman et al., 2002 | Serum | | Serum | | Pos
Bowman et al., 2002 | | | | | Equiv
Bowman et al., 2002 | | | | | Neg
Bowman et al., 2002 | FISH | | FISH | | Pos
Bowman et al., 2002 | | | | | Equiv
Bowman et al., 2002 | | | | | Neg
Bowman et al., 2002 | IHC | Neomarkers CB11 | IHC | continuous variable with no cutoff | Pos
Bowman et al., 2002 | | | | | Equiv
| | | | Neg
Campos et al., 2001 | Serum | | Serum | | Pos
Campos et al., 2001 | | | | | Equiv
Campos et al., 2001 | | | | | Neg
Campos et al., 2001 | FISH | | FISH | | Pos
Campos et al., 2001 | | | | | Equiv
Campos et al., 2001 | | | | | Neg
Campos et al., 2001 | IHC | IMPATH with Dako HercepTest | IHC | ≥ 1+ | Pos | 9
Campos et al., 2001 | | | | | Equiv
| | | | Neg | 91
Hengstler et al., 1999 | Serum | | Serum | | Pos | | c-erbB-2 (HER2) expression
Hengstler et al., 1999 | | | | Equiv | | analyzed by reverse
Hengstler et al., 1999 | | | | | Neg | | semiquantitative PCR
Hengstler et al., 1999 | FISH | | FISH | | Pos
Hengstler et al., 1999 | | | | | Equiv
Hengstler et al., 1999 | | | | | Neg
Hengstler et al., 1999 | IHC | | IHC | continuous | Pos
Hengstler et al., 1999 | | | | | Equiv
| | | | Neg
Di Leo et al., 1995 | Serum | | Serum | | Pos
Di Leo et al., 1995 | | | | | Equiv
Di Leo et al., 1995 | | | | | Neg
Di Leo et al., 1995 | FISH | | FISH | | Pos
Di Leo et al., 1995 | | | | | Equiv
Di Leo et al., 1995 | | | | | Neg
Di Leo et al., 1995 | IHC | Triton | IHC | ≥ 10% staining | Pos | 14
Di Leo et al., 1995 | | Diagnostics | | | Equiv
| pAbl | | | Neg | 86

Table V-O Ovarian Cancer. Outcome Assessment

Study | Primary Outcomes | Secondary Outcomes | Response Criteria | Independent Response Assessor | F/U Frequency/Duration
9040, Camilleri-Broet et al., 2004 | | Response, OS, PFS | ≥ 50% reduction in product of tumor measurements and no appearance of new lesions, evaluated clinically or by laparotomy | | med 68 mo
10820, Bookman et al., 2003 | ORR (CR + PR) | PFS, toxicity | CR = disappearance for ≥ 4 wks PR = ≥ 50%↓ ID = ≥ 50%↑ PD = increasing disease or death due to disease prior to tumor assessment
11720, Bowman et al., 2002 | | ORR, TTP, OS, failure-free at 12 wks | UICC Rustin's (CA125) | | med 24 mo (rng 11–35 mo)
13450, Campos et al., 2001 | | ORR, CA-125, OS, TTPtoxicity | Rustin's (CA125) For pts with measurable disease: CR = disappearance of measurable disease and CA125 < 35 U/ml for ≥ 30 days after tx PR = > 50%↓ of measurable disease for ≥ 30 days and CA125 ↓ > 50% SD = response < PR without PD for at least 3 wk PD = > 25%↑ of measurable disease and CA125 ↑ > 25% or new disease sites on clinical exam For pts w/out measurable disease: CR = normalization of CA125 and complete resolution of pleural ascites/fluid (if present) PR = > 50%↓ of CA125 with reduction of ascites/pleural fluid PD = same as pts with measurable disease | | med 22 mo
15150, Hengstler et al., 1999 | OS
17300, Di Leo et al., 1995 | | Toxicity, ORR, TTF, OS | WHO criteria for response (not shown in paper)

Table V-p Ovarian Cancer. Time to Event Outcomes

Study | Time to Event Outcomes
Camilleri-Broet et al., 2004 cisplatin + epirubicin + cyclophosphamide | Outcome | Grp | N | Med (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | Test | p | RR (95%CI) | Comments
Camilleri-Broet et al., 2004 cisplatin + epirubicin + cyclophosphamide | PFS | HER2+ pts | 15 | 12 | ~58 | ~8 | 0 | | | Cox | 0.02 | 2.13 (1.13–4.01) | UV
Camilleri-Broet et al., 2004 cisplatin + epirubicin + cyclophosphamide | | HER2- pts | 102 | 15 | ~70 | ~30 | ~20 | ~9 | ~6 | Cox | 0.02 | 2.08 (1.11–3.91) | MV
Camilleri-Broet et al., 2004 cisplatin + epirubicin + cyclophosphamide | OS | HER2+ pts | 15 | 25 | ~86 | ~46 | ~20 | 0 | | Cox | 0.02 | 2.07 (1.03–4.17) | UV
Camilleri-Broet et al., 2004 cisplatin + epirubicin + cyclophosphamide | | HER2- pts | 102 | 35 | ~92 | ~60 | ~46 | ~36 | ~28 | Cox | 0.04 | 2.07 (1.03–4.15) | MV
Bookman et al., 2003 trastuzumab | Outcome | Grp | N | Med (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | Test | p | HR (95%CI) | Comments no relation between tHER2 expression level and PFS/OS
Bookman et al., 2003 trastuzumab | PFS | | 41 | | | | | | | | | | Comments no relation between tHER2 expression level and PFS/OS
OS | | 41
Bowman et al., 2002 letrozole | Outcome | Grp | N | Med (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | Test | p | HR (95%CI) | Comments
Campos et al., 2001 liposomal doxorubicin | Outcome | Grp | N | Med (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | Test | p | HR (95%CI) | Comments
Hengstler et al., 1999 carboplatin or cisplatin + cyclophosphamide | Outcome | Grp | N | Med (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | Test | p | HR (95%CI) | Comments complete grp
Hengstler et al., 1999 carboplatin or cisplatin + cyclophosphamide | OS | low HER2 | 37 | 100.8 | ~80 | ~75 | ~72 | ~60 | ~52 | LR | 0.0001 | | Comments complete grp
Hengstler et al., 1999 carboplatin or cisplatin + cyclophosphamide | | interm HER2 | 19 | 63.6 | ~93 | ~81 | ~74 | ~55 | ~50 | | | | Comments complete grp
| high HER2 | 21 | 16.8 | ~63 | ~25 | ~15 | ~5 | ~5
Di Leo et al., 1995 mitoxantrone + ifosfamide | Outcome | Grp | N | Med (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | Test | p | HR (95%CI) | Comments

Table V-Q Ovarian Cancer. Time to Event Outcome Regression Modeling

Study | Design/Outcome/Model | Candidate Predictors/Method for Identifying Candidates | Univariate Results, Variable (p value) | Selected Predictors/Methods for Selecting Predictors for Multivariate Model | Proportional Hazards Assumption Assessed?/Interactions Considered? | Multivariate Model Results, Variable (p value) | Discrimination/Validation Methods/Results | Calibration/Goodness of Fit
9040, Camilleri-Broet et al., 2004 | RET/PFS, OS/Cox | ? | ? | based on UV PFS: PS, ascites, residual lesion size, HER2 OS: PS, ascites, residual lesion size, HER2 | ? | PFS:ascites (<0.01), HER2 (0.02) OS: ascites (0.04), HER2 (0.04) | N | ?
10820, Bookman et al., 2003
11720, Bowman et al., 2002
13450, Campos et al., 2001
15150, Hengstler et al., 1999
17300, Di Leo et al., 1995 | RET/TTF, OS/Cox recurs part | imaging, tumor grade, residual tumor volume, age, disease sites, tumor responsiveness, p53, HER2 | TTF: disease detectable on imaging (0.02) OS: (0.01) | TTF: disease detectable on imaging OS: same | ? | TTF: disease detectable on imaging OS: same

Table V-R Ovarian Cancer. Tumor Response and Quality of Life

Study | Tumor Response (%) | | | | | | | | | | Quality of Life
9040, Camilleri-Broet et al., 2004 | Grp | N | CR | PR | SD | PD | | Test | p | Comments no relation between tHER2 expression level and response; | Scale | Domain | F/U | Grp | n | mn±sd
10820, Bookman et al., 2003 | Grp | N | CR | PR | SD | PD | | Test | p | Comments IHC3+ more likely to experience cycle 1 toxicity | Scale | Domain | F/U | Grp | n | mn±sd
| | | | | | | | 0.023
11720, Bowman et al., 2002 | Grp | N | CR+PR | | SD | PD | ? | Test | p | Comments high HER2 (not defined) associated with CA125 progression | Scale | Domain | F/U | Grp | n | mn±sd
| | | | | | | | 0.026
13450, Campos et al., 2001 | Grp | N | CR | PR | SD | PD | | Test | p | Comments ≥50%↓ in CA125 | Scale | Domain | F/U | Grp | n | mn±sd
13450, Campos et al., 2001 | IHC+ | 4 | 50 | | | 50 | | FE | 0.579 | Comments ≥50%↓ in CA125
13450, Campos et al., 2001 | IHC- | 30 | 30 | | 11 | 57 | 2 | | | Comments ≥50%↓ in CA125
IHC? | 24 | 17 | | 29 | 50 | 4
15150, Hengstler et al., 1999 | Grp | N | CR+PR | | SD+PD | | | Test | p | Comments | Scale | Domain | F/U | Grp | n | mn±sd
17300, Di Leo et al., 1995 | Grp | N | CR | PR | SD | PD | | Test | p | Comments | Scale | Domain | F/U | Grp | n | mn±sd
17300, Di Leo et al., 1995 | IHC+ | 8 | 25 | | 75 | | | FE | 0.602 | Comments
IHC- | 14 | 14 | | 86

Table V-S Ovarian Cancer. : Response Regression Modeling

Study | Design/Outcome/Model | Candidate Predictors/Method for Identifying Candidates | Univariate Results, Variable (p value) | Selected Predictors/Methods for Selecting Predictors for Multivariate Model | Interactions Considered? | Multivariate Model Results, Variable (p value) | Discrimination/Validation Methods/Results | Calibration/Goodness of Fit
9040, Camilleri-Broet et al., 2004
10820, Bookman et al., 2003
11720, Bowman et al., 2002
13450, Campos et al., 2001
15150, Hengstler et al., 1999
17300, Di Leo et al., 1995

Table V-T Ovarian Cancer. Adverse Events

Toxicity Type | Study | Severity or Grade | Results
Treatment-related mortality | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Nausea | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Vomiting | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Anorexia | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Lethargy | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Neurosensory | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Hearing loss | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Cardiac ischemia | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Diminished LVEF | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Arrhythmias | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Bronchopulmonary | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Dermatologic | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Kidney | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Anemia | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Thrombocytopenia | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Leukopenia or neutropenia | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Infection | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Other | | | F/U (mo) | Grp1 n | % | Grp2 n | %

Table V-U Ovarian Cancer. Randomized Trial Study Quality Ratings

Study | Initial Assembly of Comparable Groups | Low Loss to Followup, Maintenance of Comparable Groups | Measurements Reliable, Valid, Equal | Interventions Comparable/Clearly Defined | Appropriate Analysis of Results | Overall Rating | Funding/Sponsorship Source Acknowledged

Table V-V Ovarian Cancer. Case Series/Single Arm Trial Study Quality Ratings

Study | Clearly Defined Question | Well-Described Study Population | Well-Described Intervention | Use of Validated Outcome Measures (Independently Assessed) | Appropriate Statistical Analysis | Well-Described Results | Discussion/Conclusions Supported by Data | Funding/Sponsorship Source Acknowledged
9040, Camilleri-Broet et al., 2004 | +/- | + | + | + (-) | + | +/- | + | +
10820, Bookman et al., 2003 | + | + | + | + (-) | - ? | + | + | +
11720, Bowman et al., 2002 | + | - | + | + (-) | - | + | + | +
13450, Campos et al., 2001 | + | - | + | + (-) | -? | + | +/- | +
15150, Hengstler et al., 1999 | + | - | + | + (-) | + | - | + | -
17300, Di Leo et al., 1995 | + | + | + | + (-) | +? | +/- | + | +

Table V-W Prostate Cancer. Design, Enrollment and Treatment

Study | Design | Therapeutic Setting | n, Enrolled (Randomized) | n, Evaluated | n, Withdrawn (Lost to F/U) | Treatment Regimen (Agents)
1320, Nishio et al., 2006 | retrospective | bone metastatic prostate cancer | 50 | 49 | 1, indeterminate tHER2 staining | maximal androgen blockade as follows: n = 47 antiandrogens + LH-RH agonists n = 3 antiandrogens + bilateral orchiectomy
16450, Arai et al., 1997 | retrospective | histologically diagnosed, untreated prostate cancer | 71 | 33 of 40 with stage D2 disease | 38, not followed for response | all pts with stage D2 disease received antiandrogen tx, including bilateral orchiectomy, leuprorelin acetate, or DES
18080, Fox et al., 1994 | Retrospective | untreated prostate cancer | 45 | 45 | 0 | expectant

Table V-X Prostate Cancer. Patient Characteristics

Study | Age | | Race (%) | | Disease Stage | | | Performance Status | | PSA | | | Gleason Score
1320, Nishio et al., 2006 | | HER2+ | | | | HER2+ | HER2- | Scale | Grp1 | Grp1 | | | | HER2+ | HER2-
1320, Nishio et al., 2006 | | (n = 21) | B | | T1c | 4.8 | 3.6 | | | HER2+ | | | 7 | 4.8 | 10.7
1320, Nishio et al., 2006 | mn | 74.4 | W | | T2a | 4.8 | 14.3 | | | mn | 798.5 | | 8 | 42.9 | 28.6
1320, Nishio et al., 2006 | md | 72 | H | | T2b | 23.8 | 25.0 | | | md | 426 | | 9 | 38.1 | 60.7
1320, Nishio et al., 2006 | rng | 63–85 | A | | T3a | 0 | 0 | | | rng | 34–3780 | | 10 | 14.3 | 0
1320, Nishio et al., 2006 | sd | 6.5 | O | | T3b | 9.5 | 10.7 | | | sd | 1076.2
1320, Nishio et al., 2006 | | | | | T4 | 52.4 | 46.4
1320, Nishio et al., 2006 | | HER2- | | | Tx | 4.8 | 0 | | | HER2-
1320, Nishio et al., 2006 | | (n = 28) | | | | | | | | mn | 1242.3
1320, Nishio et al., 2006 | mn | 73.0 | | | N0 | 52.4 | 67.9 | | | md | 270.4
1320, Nishio et al., 2006 | md | 72 | | | N1 | 42.9 | 32.1 | | | rng | 37–10060
1320, Nishio et al., 2006 | rng | 61–91 | | | N2 | 4.8 | 0 | | | sd | 2323.6
sd | 7.9
16450, Arai et al., 1997 | | Grp1 | | Grp1 | | Grp1 | | Scale | Grp1 | | | Grp1 | | | | Grp1
16450, Arai et al., 1997 | mn | | B | | Whitmore-Jewett system | | | | | mn
16450, Arai et al., 1997 | md | | W | | B | 8.5 | | | | md
16450, Arai et al., 1997 | rng | | H | | C | 26.8 | | | | rng
16450, Arai et al., 1997 | sd | | A | | D1 | 8.5 | | | | sd
| | O | | D2 | 56.3
18080, Fox et al., 1994 | | Grp1 | | Grp1 | | Grp1 | | Scale | Grp1 | | | Grp1 | | | | Grp1
18080, Fox et al., 1994 | mn | 65 | B | | A1 | 100 | | | | mn | | | all < 4
18080, Fox et al., 1994 | md | | W | | | | | | | md
18080, Fox et al., 1994 | rng | 54–75 | H | | | | | | | rng
18080, Fox et al., 1994 | sd | | A | | | | | | | sd
| | O

Table V-Y Prostate Cancer. HER2 Measurement Methods

Study | Assays (Name) | | Criteria for Positivitv | | Test Results (%) | | Comments
1320, Nishio et al., 2006 | Serum | | Serum | | Pos
1320, Nishio et al., 2006 | | | | | Equiv
1320, Nishio et al., 2006 | | | | | Neg
1320, Nishio et al., 2006 | FISH | | FISH | | Pos
1320, Nishio et al., 2006 | | | | | Equiv
1320, Nishio et al., 2006 | | | | | Neg
1320, Nishio et al., 2006 | IHC | K5205 (Dako HercepTest) | IHC | weak to moderate or strong complete membrane staining in > 10% of tumor cells (> 1+) | Pos | 42
1320, Nishio et al., 2006 | | | | weak to moderate or strong complete membrane staining in > 10% of tumor cells (> 1+) | Equiv | 2
1320, Nishio et al., 2006 | | | | weak to moderate or strong complete membrane staining in > 10% of tumor cells (> 1+) | Neg | 56
16450, Arai et al., 1997 | Serum | SV2-61Y and 6G10 (Eiken Chemical Co. Tokyo, Japan) | Serum | > 3.7 ng/mL | Pos | 30 | 71 treated pts had serum assay data plus 161 additional patients
16450, Arai et al., 1997 | | | | | Equiv | | 71 treated pts had serum assay data plus 161 additional patients
16450, Arai et al., 1997 | | | | | Neg | 70 | 71 treated pts had serum assay data plus 161 additional patients
16450, Arai et al., 1997 | FISH | | FISH | | Pos | | 71 treated pts had serum assay data plus 161 additional patients
16450, Arai et al., 1997 | | | | | Equiv | | 71 treated pts had serum assay data plus 161 additional patients
16450, Arai et al., 1997 | | | | | Neg | | 71 treated pts had serum assay data plus 161 additional patients
16450, Arai et al., 1997 | IHC | | IHC | | Pos | | 71 treated pts had serum assay data plus 161 additional patients
16450, Arai et al., 1997 | | | | | Equiv | | 71 treated pts had serum assay data plus 161 additional patients
| | | | Neg
18080, Fox et al., 1994 | Serum | | Serum | | Pos
18080, Fox et al., 1994 | | | | | Equiv
18080, Fox et al., 1994 | | | | | Neg
18080, Fox et al., 1994 | FISH | | FISH | | Pos
18080, Fox et al., 1994 | | | | | Equiv
18080, Fox et al., 1994 | | | | | Neg
18080, Fox et al., 1994 | IHC | CB11(Novacostra Lab) | IHC | membrane or cytoplasmic staining in > 10% of tumor cells | Pos | 36
18080, Fox et al., 1994 | | | | membrane or cytoplasmic staining in > 10% of tumor cells | Equiv
| | | Neg | 64

Table V-Z Prostate Cancer. Outcome Assessment

Study | Primary Outcomes | Secondary Outcomes | Response Criteria | Independent Response Assessor | F/U Frequency/Duration
1320, Nishio et al., 2006 | | cause-specific survival (CSS) RFS | | | med | 48.7 mo
rng | 6.9–79.4 mo
16450, Arai et al., 1997 | | PFS
18080, Fox et al., 1994 | | OS | | | rng 3–216 mo (3–12 mo intervals)

Table V-AA Prostate Cancer. Time to Event Outcomes

Study
1320, Nishio et al., 2006 | Outcome | Grp | N | Med (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | Test | p | HR (95%CI) | Comments
1320, Nishio et al., 2006 | CSS | HER2+ | 21 | ~ 32 | 100 | ~ 60 | ~ 41 | ~ 39 | 21.2 | log-rank | 0.0084
1320, Nishio et al., 2006 | | HER2- | 28 | NR | ~ 92 | ~ 80 | ~ 70 | ~ 60 | 63.2
1320, Nishio et al., 2006 | RFS | HER2+ | 21 | ~ 9 | ~ 42 | ~ 32 | 23.8 | ~ 15 | 0 | log-rank | 0.0485
| HER2- | 28 | ~ 19 | ~ 73 | ~ 45 | 35.7 | ~ 28 | ~ 23
16450, Arai et al., 1997 | Outcome | Grp | N | Med (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | Test | p | HR (95%CI) | Comments
16450, Arai et al., 1997 | PFS | HER2+ | 11 | ~ 9 | ~ 30 | ~ 10 | ~ 10 | | | log-rank | <0.05
| HER2- | 22 | ~ 15 | ~ 60 | ~ 38 | ~ 38 | ~ 38
18080, Fox et al., 1994 | Outcome | Grp | N | Med (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | Test | p | HR (95%CI) | Comments
18080, Fox et al., 1994 | OS | HER2+ | 16 | ~ 35 | ~ 87 | ~ 80 | ~ 47 | ~ 38 | ~ 38 | W-G | 0.0316
| HER2- | 29 | ~ 162 | ~ 93 | ~ 88 | ~ 89 | ~ 84 | ~ 84

Table V-BB Prostate Cancer. Time to Event Outcome Regression Modeling

Study | Design/Outcome/Model | Candidate Predictors/Method for Identifying Candidates | Univariate Results, Variable (p value) | Selected Predictors/Methods for Selecting Predictors for Multivariate Model | Proportional Hazards Assumption Assessed?/Interactions Considered? | Multivariate Model Results, Variable (p value) | Discrimination/Validation Methods/Results | Calibration/Goodness of Fit
1320, Nishio et al., 2006
16450, Arai et al., 1997
18080, Fox et al., 1994

Table V-CC Prostate Cancer. Tumor Response and Quality of Life

Study | Tumor Response (%) | | | | | | | | | Quality of Life
1320, Nishio et al., 2006 | Grp | N | CR | PR | SD | PD | Test | p | Comments | Scale | Domain | F/U | Grp | n | mn±sd
16450, Arai et al., 1997 | Grp | N | CR | PR | SD | PD | Test | p | Comments | Scale | Domain | F/U | Grp | n | mn±sd
18080, Fox et al., 1994 | Grp | N | CR | PR | SD | PD | Test | p | Comments | Scale | Domain | F/U | Grp | n | mn±sd

Table V-DD Prostate Cancer. Response Regression Modeling

Study | Design/Outcome/Model | Candidate Predictors/Method for Identifying Candidates | Univariate Results, Variable (p value) | Selected Predictors/Methods for Selecting Predictors for Multivariate Model | Interactions Considered? | Multivariate Model Results, Variable (p value) | Discrimination/Validation Methods/Results | Calibration/Goodness of Fit
1320, Nishio et al., 2006 | retrospective
16450, Arai et al., 1997 | case series
18080, Fox et al., 1994 | retrospective

Table V-EE Prostate Cancer. Adverse Events

Toxicity Type | Study | Severity or Grade | Results
Treatment-related mortality | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Nausea | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Vomiting | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Anorexia | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Lethargy | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Neurosensory | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Hearing loss | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Cardiac ischemia | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Diminished LVEF | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Arrhythmias | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Bronchopulmonary | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Dermatologic | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Kidney | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Anemia | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Thrombocytopenia | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Leukopenia or neutropenia | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Infection | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Other | | | F/U (mo) | Grp1 n | % | Grp2 n | %

Table V-FF Prostate Cancer. Randomized Trial Study Quality Ratings

Study | Initial Assembly of Comparable Groups | Low Loss to Followup, Maintenance of Comparable Groups | Measurements Reliable, Valid, Equal | Interventions Comparable/Clearly Defined | Appropriate Analysis of Results | Overall Rating | Funding/Sponsorship Source Acknowledged

Table V-GG Prostate Cancer. Case Series/Single Arm Trial Study Quality Ratings

Study | Clearly Defined Question | Well-Described Study Population | Well-Described Intervention | Use of Validated Outcome Measures (Independently Assessed) | Appropriate Statistical Analysis | Well-Described Results | Discussion/Conclusions Supported by Data | Funding/Sponsorship Source Acknowledged
1320, Nishio et al., 2006 | + | + | +/- | + (-) | + ? | +/- | + | -
16450, Arai et al., 1997 | - | - | +/- | + (-) | + | - | + | +
18080, Fox et al., 1994 | + | - | +/- | + (-) | + | + | + | +

Table V-HH Head and Neck Cancer. Design, Enrollment and Treatment

Study | Design | Therapeutic Setting | n, Enrolled (Randomized) | n, Evaluated | n, Withdrawn (Lost to F/U) | Treatment Regimen (Agents)
24520, Nagler et al., 2003 1 center in Israel | RET CS | Malignant salivary tumors | 36 | 36 | | Surgery, no adjuvant therapy
25490, Khan et al., 2002 1981-1992, 1 US center | RET CS | SCC of oral cavity (57%) or oropharynx (43%) | 77 | 56 | 14 incomplete f/u; 10 samles unvailable | Primary surgical excision and EBRT with curative intent

Table V-II Head and Neck Cancer. Patient Characteristics

Study | Age | | % Female | Race (%) | | Disease Stage | | Performance Status | | Comorbidities or Other Prognostic Factors
24520, Nagler et al., 2003 | | Grp1 | Grp1 | | Grp1 | | Grp1 | Scale | Grp1 | Tumor Grade | Grp1
24520, Nagler et al., 2003 | mn | 56 | 45 | Jews | 97 | Ia
24520, Nagler et al., 2003 | md | | | Arabs | 3 | Ib
24520, Nagler et al., 2003 | rng | 15–79 | | | | IIa
24520, Nagler et al., 2003 | sd | 4 | | | | IIb
24520, Nagler et al., 2003 | >60 | 45% | | | | IIIa
24520, Nagler et al., 2003 | | | | | | IIIb
| | | | | IV
25490, Khan et al., 2002 | | Grp1 | Grp1 | | Grp1 | | Grp1 | Scale | Grp1 | Tumor Grade | Grp1
25490, Khan et al., 2002 | mn | | 18 | B | 16 | T1–2 | 34
25490, Khan et al., 2002 | md | | | W | 84 | T3–4 | 66
25490, Khan et al., 2002 | rng | | | H | | N0 | 18
25490, Khan et al., 2002 | sd | | | A | | N1 | 43
25490, Khan et al., 2002 | | | | O | | N2–3 | 39
25490, Khan et al., 2002 | 41–56 | 25% | | | | II | 9
25490, Khan et al., 2002 | 56–59 | 25% | | | | III | 28
25490, Khan et al., 2002 | 59–66 | 25% | | | | IV | 63
66–79 | 25%

Table V-JJ Head and Neck Cancer. HER2 Measurement Methods

Study | Assays (Name) | | Criteria for Positivity | | Test Results (%) | | Comments
24520, Nagler et al., 2003 | Serum: | | Serum | | Pos
24520, Nagler et al., 2003 | | | | | Equiv
24520, Nagler et al., 2003 | | | | | Neg
24520, Nagler et al., 2003 | FISH | | FISH | | Pos
24520, Nagler et al., 2003 | | | | | Equiv
24520, Nagler et al., 2003 | | | | | Neg
24520, Nagler et al., 2003 | IHC: | Dako polyclonal | IHC | > 10% staining, moderate to strong (1/2) | Pos | 28
24520, Nagler et al., 2003 | | | | > 10% staining, moderate to strong (1/2) | Equiv
| | | Neg | 72
25490, Khan et al., 2002 | Serum: | | Serum | | Pos
25490, Khan et al., 2002 | | | | | Equiv
25490, Khan et al., 2002 | | | | | Neg
25490, Khan et al., 2002 | FISH | PathVysion | FISH | HER2:CEP17 > 2 | Pos | 4/16 (25%) | quantifiable signal in 16 of 19
25490, Khan et al., 2002 | | | | | Equiv
25490, Khan et al., 2002 | | | | | Neg
25490, Khan et al., 2002 | IHC: | CB 11, > 10% staining, moderate (2+), strong (3+), intense (4+) | IHC | ≥ 2+ | Pos | 12/67 (18%) | discrepant text says 67 or 69 total tested
25490, Khan et al., 2002 | | | | | Equiv | 4/67 (6%)
| | | | Neg | 53/67 (79%)

Table V-KK Head and Neck Cancer. Outcome Assessment

Study | Primary Outcomes | Secondary Outcomes | Response Criteria | Independent Response Assessor | F/U Frequency/Duration
24520, Nagler et al., 2003 | OS
25490, Khan et al., 2002 | Local recurrence, regional recurrence, distant recurrence, DFS, OS | | ? | NR

Table V-LL Head and Neck Cancer. Time to Event Outcomes

Study | Time to Event Outcomes
24520, Nagler et al., 2003 | Outcome | Grp | N | Med (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | Test | p | HR (95%CI) | Comments
24520, Nagler et al., 2003 | OS | IHC+ | 10 | | | | | | 30 | LR | 0.0004
| IHC- | 26 | | | | | | 72
25490, Khan et al., 2002 | Outcome | Grp | N | Med (mos) | 1 yr | 2 yr | 3 yr | 4 yr | 5 yr | Test | p | RR (95%CI) | Comments
25490, Khan et al., 2002 | DFS | IHC+ vs - | ? | | | | | | | UV Cox | | 0.83 (0.29, 2.4)
25490, Khan et al., 2002 | OS | IHC+ vs - | ? | | | | | | | UV Cox | | 1.4 (0.62, 3.3)
25490, Khan et al., 2002 | OS | FISH disom/- | 47 | 5.8 | | | | | 43
25490, Khan et al., 2002 | | FISH polysom | 5 | 3.1 | | | | | 40 | LR | 0.15 | | LR test for combined disomic, non-overexpressed + polysomic
| FISH+ | 4 | 2.2 | | | | | 0

Table V-MM Head and Neck Cancer. Time to Event Outcome Regression Modeling

Study | Design/Outcome/Model | Candidate Predictors/Method for Identifying Candidates | Univariate Results, Variable (p value) | Selected Predictors/Methods for Selecting Predictors for Multivariate Model | Proportional Hazards Assumption Assessed?/Interactions Considered? | Multivariate Model Results, Variable (p value) | Discrimination/Validation Methods/Results | Calibration/Goodness of Fit
24520, Nagler et al., 2003
25490, Khan et al., 2002

Table V-NN Head and Neck Cancer. Tumor Response and Quality of Life

Study | Tumor Response (%) | | | | | | | | | Quality of Life
24520, Nagler et al., 2003 | Grp | N | CR | PR | SD | PD | Test | p | Comments | Scale | Domain | F/U | Grp | n | mn±sd
25490, Khan et al., 2002 | Grp | N | CR | PR | SD | PD | Test | p | Comments | Scale | Domain | F/U | Grp | n | mn±sd

Table V-OO Head and Neck Cancer. Response Regression Modeling

Study | Design/Outcome/Model | Candidate Predictors/Method for Identifying Candidates | Univariate Results, Variable (p value) | Selected Predictors/Methods for Selecting Predictors for Multivariate Model | Interactions Considered? | Multivariate Model Results, Variable (p value) | Discrimination/Validation Methods/Results | Calibration/Goodness of Fit
24520, Nagler et al., 2003
25490, Khan et al., 2002

Table V-PP Head and Neck Cancer. Adverse Events

Toxicity Type | Study | Severity or Grade | Results
Treatment-related mortality | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Nausea | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Vomiting | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Anorexia | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Lethargy | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Neurosensory | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Hearing loss | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Cardiac ischemia | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Diminished LVEF | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Arrhythmias | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Bronchopulmonary | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Dermatologic | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Kidney | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Anemia | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Thrombocytopenia | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Leukopenia or neutropenia | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Infection | | | F/U (mo) | Grp1 n | % | Grp2 n | %
Other | | | F/U (mo) | Grp1 n | % | Grp2 n | %

Table V-QQ Head and Neck Cancer. Randomized Trial Study Quality Ratings

Study | Initial Assembly of Comparable Groups | Low Loss to Followup, Maintenance of Comparable Groups | Measurements Reliable, Valid, Equal | Interventions Comparable/Clearly Defined | Appropriate Analysis of Results | Overall Rating | Funding/Sponsorship Source Acknowledged

Table V-RR Head and Neck Cancer. Case Series/Single Arm Trial Study Quality Ratings

Study | Clearly Defined Question | Well-Described Study Population | Well-Described Intervention | Use of Validated Outcome Measures (Independently Assessed) | Appropriate Statistical Analysis | Well-Described Results | Discussion/Conclusions Supported by Data | Funding/Sponsorship Source Acknowledged
24520, Nagler et al., 2003
25490, Khan et al., 2002