# Appendix B. Listing of Excluded Studies

## Exclusion Codes

[underlined: Retrieval Code] (field 12)
GET | retrieve full copy
DNG | do not retrieve full copy
UNC | uncertain; needs check by second reviewer
[underlined: Selection Decision Code] (field 12)
INC | include
EXC | exclude (with codes for exclusion reasons)
[underlined: Full Review Codes] (field 42)
I. Key Question Codes
Q1 | breast tissue HER2, accuracy/concordance,
Q2A | breast tissue HER2 discrepant, trastuzumab therapy
Q2B | breast tissue HER2 negative, trastuzumab therapy
Q2AB | either/both Q2A and Q2B
Q3A | breast tissue HER2 status, chemotherapy
Q3B | breast tissue HER2 status, hormonal therapy
Q3AB | either/both Q3A and Q3B
Q4 | breast serum HER2
Q5S | serum HER2, non-breast solid tumors
Q5T | tissue HER2, non-breast solid tumors
Q5ST | serum & tissue HER2, non-breast solid tumors
NRQ | not relevant question (note if NDE, INV, ANM, HNM, NRD, NRO, NRT, NRS, NIT)
Q#? | unclear if relevant to any key question
II. Study Design Codes
RCT | randomized controlled trial
PRO | prospective single-arm study
PI | phase I trial
PII | phase II trial
QEX | quasi-experimental study (nonrandomized comparative)
DAC | diagnostic accuracy/concordance study
ADS | assay development study
RET | retrospective study
CR | case report (n≤5)
CS | case series
PRG | prognostic study
ADB | administrative database
REG | registry
SR | systematic review
NPD | no primary data
NRA | narrative review article (GET only if helps for Intro; DNG if 2002 or earlier)
MA | meta-analysis
CEA | cost-effectiveness analysis
D? | design unclear/possibly relevant
LTR | letter
EDT | editorial
NDE | not relevant design
ICT | incomplete cross-tabluation of assay results
HNM | HER-2 not measured
INV | in vitro study
ANM | animal model study
III. Sample Size Code (single-arm only)
FEW | n < 25
N25 | 25 ≤ n ≤ 49
N50 | 50 ≤ n ≤ 99
N100 | n ≥ 100
N? | n unclear
IV. Disease/Outcome/Intervention Codes
BC | breast cancer
OST | other solid tumor
NST | non-solid tumor
DS? | disease unclear
NRD | not relevant disease
O? | outcome unclear
NRO | not relevant outcome (or no follow-up)
NRS | no relevant subgroup analysis for outcomes
FU? | follow-up uncertain
TRZ | trastuzumab-based treatment
CHT | chemotherapy
HT | hormonal therapy
T? | treatment unclear
NRT | not relevant treatment
NIT | not identically treated
IT? | uncertain whether identically treated
PC | prostate cancer
LC | lung cancer
HNC | head & neck cancer
OC | ovarian cancer
V. HER2 Assay Method Codes
IHC | immunohistochemistry, one antibody or antiserum
WBL | Western blot (measures HER2 protein)
MAB | IHC comparing ≥2 antibodies or antisera
FIS | fluorescence in-situ hybridization
CIS | chromogenic in-situ hybridization
PCR | polymerase chain reaction
RNA | dot-blot or other methods for mRNA assay (including rt-PCR)
OTH | any other HER2 assay methods
TMA | tissue micro-array methods
MNV | assay method not adequately validated, quality assured, etc.
MV? | uncertain assay method validation, quality assurance
OBF | other body fluid (not serum or plasma)
HM? | HER2 assay method unclear
ELS | ELISA or other enzyme assay
CTC | circulating tumor cells
SBL | Southern blot

### References

OSI Pharmaceuticals. Genentech and Roche announce data from clinical studies of Tarceva. Expert Rev Anticancer Ther. 2001;1(1):4-5. Notes: Q? D? DS?.
Temporary treatment protocol trastuzumab (Herceptin(registered trademark)) for back-up: PROTOCOLE TEMPORAIRE DE TRAITEMENT TRASTUZUMAB (HERCEPTIN(registered trademark)) EN SITUATION ADJUVANTE. Oncologie 2005; 7(SUPPL. 2):s86–s99. Notes: Q2A? NRA (practice guideline)
Abendstein B, Daxenbichler G, Windbichler G, et al. Predictive value of uPA, PAI-1, HER-2 and VEGF in the serum of ovarian cancer patients. Anticancer Res. 2000;20(1 B):569-72. Notes: Q5 CS N50 OC. [pmid: 10769727].
Aebersold DM, Froehlich SC, Jonczy M, et al. Expression of transforming growth factor-alpha, epidermal growth factor receptor and platelet-derived growth factors A and B in oropharyngeal cancers treated by curative radiation therapy. Radiother Oncol. 2002;63(3):275-83. Notes: Q5 CS N50 HNC. [pmid: 12142091].
Agrup M, Stal O, Olsen K, Wingren S. C-erbB-2 overexpression and survival in early onset breast cancer. Breast Cancer Res Treat. 2000;63(1):23-9. Notes: Q3A? RET N100 BC IT? IHC. [pmid: 11079156].
Ahn JH, Kim SW, Hong SM, et al. Epidermal growth factor receptor (EGFR) expression in operable non-small cell lung carcinoma. J Korean Med Sci. 2004;19(4):529-35. Notes: Q5? RET CS N50 LC IT?. [pmid: 15308843].
7 Ahnstrom M, Nordenskjold B, Rutqvist LE, Skoog L, Stal O. Role of cyclin D1 in ErbB2-positive breast cancer and tamoxifen resistance. Breast Cancer Res Treat. 2005;91(2):145-51. Notes: Q3AB? RCT N100 BC CHT HT IHC. [pmid: 15868442].
Akamatsu M, Matsumoto T, Oka K, et al. c-erbB-2 oncoprotein expression related to chemoradioresistance in esophageal squamous cell carcinoma. Int J Radiat Oncol Biol Phys. 2003;57(5):1323-7. Notes: Q5 CS N25 HNC CHT RT. [pmid: 14630269].
Akslen LA, Myking AO, Salvesen H, Varhaug JE. Prognostic impact of EGF-receptor in papillary thyroid carcinoma. Br J Cancer. 1993;68(4):808-12. Notes: Q5 CS? N? HNC IT?. [pmid: 8398712].
Akslen LA, Varhaug JE. Oncoproteins and tumor progression in papillary thyroid carcinoma: presence of epidermal growth factor receptor, c-erbB-2 protein, estrogen receptor related protein, p21-ras protein, and proliferation indicators in relation to tumor recurrences and patient survival. Cancer. 1995;76(9):1643-54. Notes: Q5 RET CS N100 HNC NRS?. [pmid: 8635070].
Al-azawi D, Kelly G, Myers E, et al. CA 15-3 is predictive of response and disease recurrence following treatment in locally advanced breast cancer. BMC Cancer. 2006;6:220. Notes: Q3A? D? N50 BC IT? HM?. [pmid: 16953875]. [pmcid: 1590047].
Aldecoa B, Garcia Adanez J, Allende MT, Ruibal A. HER 2/Neu determination in ovaric pathology: DETERMINACION DEL HER 2/NU EN LA PATOLOGIA OVARICA. PROG OBSTET GINECOL. 1996;39(7):507-14. Notes: Q5 PRO CS N25 OC IT?.
Ali-Fehmi R, Che M, Khalifeh I, et al. The effect of cyclooxygenase-2 expression on tumor vascularity in advanced stage ovarian serous carcinoma. Cancer. 2003;98(7):1423-9. Notes: Q5? CS N100 OC IT? NRS?. [pmid: 14508829].
Ali SM, Leitzel K, Chinchilli VM, et al. Relationship of serum HER-2/neu and serum CA 15-3 in patients with metastatic breast cancer. Clin Chem. 2002;48(8):1314-20. Notes: Q4? RCT N100 BC HT ELS. [pmid: 12142389].
Allan SG, Hay FG, McIntyre MA, Leonard RC. Prognosis in small cell carcinoma of the lung—relationship to human milk fat globule 2 (HMFG2) antigen and other small cell associated antigens. Br J Cancer. 1987;56(4):485-8. Notes: Q5? CS N25 IT? LC. [pmid: 2825751].
Allred DC, Clark GM, Tandon AK, et al. HER-2/neu in node-negative breast cancer: prognostic significance of overexpression influenced by the presence of in situ carcinoma. J Clin Oncol. 1992;10(4):599-605. Notes: Q3A RCT N100 BC IHC Q3? IT?. [pmid: 1548522].
Almadori G, Cadoni G, Galli J, et al. Epidermal growth factor receptor expression in primary laryngeal cancer: An independent prognostic factor of neck node relapse. Int J Cancer. 1999;84(2):188-91. Notes: Q5 CS N100 HNC. [pmid: 10096253].
Almadori G, Cadoni G, Maurizi M, et al. [Oncogenes and cancer of the larynx. EGFR, p21 ras and HPV-DNA infections]. Acta Otorhinolaryngol Ital. 1995;15(1 Suppl 46):1-22. Notes: Q5 CS N100 HNC IT?. [pmid: 7793243].
Altundag K, Altundag O. Superiority of letrozole over tamoxifen in the first-line treatment of metastatic breast cancer patients with normal serum Her-2/neu levels: question of tamoxifen resistance. J Clin Oncol. 2003;21(24):4656. author reply 4657. Notes: Q3B?. [pmid: 14673060].
Alvarez RD, Curiel DT. A phase I study of recombinant adenovirus vector-mediated delivery of an anti-erbB-2 single-chain (sFv) antibody gene for previously treated ovarian and extraovarian cancer patients. Hum Gene Ther. 1997;8(2):229-42. Notes: Q5? PI OC GT. [pmid: 9017426].
Andersen TI, Paus E, Nesland JM, McKenzie SJ, Borresen AL. Detection of c-erbB-2 related protein in sera from breast cancer patients. Relationship to ERBB2 gene amplification and c-erbB-2 protein overexpression in tumour. Acta Oncol. 1995;34(4):499-504. Notes: Q4 RET N100 BC T? ELS. [pmid: 7605658].
Andratschke NH, Dittmann KH, Mason KA, et al. Epidermal growth factor receptor as a target to improve treatment of lung cancer. Clin Lung Cancer. 2004;5(6):340-52. Notes: Q5 NRA NPD LC. [pmid: 15217533].
Ang KK, Andratschke NH, Milas L. Epidermal growth factor receptor and response of head-and-neck carcinoma to therapy. Int J Radiat Oncol Biol Phys. 2004;58(3):959-65. Notes: Q5 NRA NPD HNC. [pmid: 14967456].
Antunes A, Silva T, Godinho I, Amaral N, Oliveira C. [Prognostic value of c-erb-2 immunohistochemistry expression in patients with primary breast cancer and adjuvant treatment with tamoxifen]. Acta Med Port. 2004;17(4):271-6. Notes: Q3B? RET N50 IT? IHC. [pmid: 15941551].
Archer CD, Parton M, Smith IE, et al. Early changes in apoptosis and proliferation following primary chemotherapy for breast cancer. Br J Cancer. 2003;89(6):1035-41. Notes: Q3A? PRO N50 BC CHT IT? IHC. [pmid: 12966422].
Arens N, Bleyl U, Hildenbrand R. HER2/neu, p53, Ki67, and hormone receptors do not change during neoadjuvant chemotherapy in breast cancer. Virchows Arch. 2005;446(5):489-96. Notes: Q3A? PRO N25 O? IT? CHT IHC FIS. [pmid: 15838646].
Arpino G, Bardou VJ, Clark GM, Elledge RM. Infiltrating lobular carcinoma of the breast: tumor characteristics and clinical outcome. Breast Cancer Res. 2004;6(3):R149-56. Notes: Q5 CS N100 BC. [pmid: 15084238].
Arriola E, Rodriguez-Pinilla SM, Lambros MB et al. Topoisomerase II alpha amplification may predict benefit from adjuvant anthracyclines in HER2 positive early breast cancer. Breast Cancer Res Treat 2007. Notes: Q3A RET N100 BC CHT CIS TMA
Asahina H, Yamazaki K, Kinoshita I, et al. A phase II trial of gefitinib as first-line therapy for advanced non-small cell lung cancer with epidermal growth factor receptor mutations. Br J Cancer. 2006;95(8):998-1004. Notes: Q5 PII FEW LC PCR. [pmid: 17047648].
Bagli L, Dittadi R, Zancan M, Panzini I, Monti F, Ravaioli A. HER-2/neu serum levels and menopausal status. Int J Biol Markers. 2001;16(1):69-70. Notes: Q4?. [pmid: 11288959].
Banerjee S, Reis-Filho JS, Ashley S, et al. Basal-like breast carcinomas: clinical outcome and response to chemotherapy. J Clin Pathol. 2006;59(7):729-35. Notes: full review: NRQ NIT from abstract: Q3AB? IT?. [pmid: 16556664].
Bartlett JM, Brawley D, Grigor K, Munro AF, Dunne B, Edwards J. Type I receptor tyrosine kinases are associated with hormone escape in prostate cancer. J Pathol. 2005;205(4):522-9. Notes: Q5 CS N25 PC. [pmid: 15685688].
Baselga J. Is circulating HER-2 more than just a tumor marker?. Clin Cancer Res. 2001;7(9):2605-7. Notes: Q4?. [pmid: 11555569].
Baselga J, Carbonell X, Castaneda-Soto NJ, et al. Phase II study of efficacy, safety, and pharmacokinetics of trastuzumab monotherapy administered on a 3-weekly schedule. J Clin Oncol. 2005;23(10):2162-71. Notes: Q1? Q2? PII N100 BC TRZ IHC FIS. [pmid: 15800309].
Baselga J, Tripathy D, Mendelsohn J, et al. Phase II study of weekly intravenous recombinant humanized anti-p185HER2 monoclonal antibody in patients with HER2/neu-overexpressing metastatic breast cancer. J Clin Oncol. 1996;14(3):737-44. Notes: Q2? PRO N25 BC TRZ IHC. [pmid: 8622019].
Baselga J, Tripathy D, Mendelsohn J, et al. Phase II study of weekly intravenous trastuzumab (Herceptin) in patients with HER2/neu-overexpressing metastatic breast cancer. Semin Oncol. 1999;26(4 Suppl 12):78-83. Notes: Q2? PII N50 BC TRZ HM?. [pmid: 10482197].
Baskic D, Ristic P, Pavlovic S, Arsenijevic N. Serum HER2 and CA 15-3 in breast cancer patients. J BU ON. 2004;9(3):289-94. Notes: Q4? N50 BC T? HM?.
Bergqvist J, Elmberger G, Ohd J, et al. Activated ERK1/2 and phosphorylated oestrogen receptor alpha are associated with improved breast cancer survival in women treated with tamoxifen. Eur J Cancer. 2006;42(8):1104-12. Notes: Q3B? RET N100 BC HT IHC. [pmid: 16603346].
Berry DA, Muss HB, Thor AD, et al. HER-2/neu and p53 expression versus tamoxifen resistance in estrogen receptor-positive, node-positive breast cancer. J Clin Oncol. 2000;18(20):3471-9. Notes: Q3AB QEX RCT N100 BC CHT HT IHC FIS PCR. [pmid: 11032587].
Bertolini A, Muffatti A, Fiumano M, et al. Hercep test in breast cancer: From bench to bedside: HERCEP TEST NEL CARCINOMA MAMMARIO: UTILIZZO CLINICO RAGIONATO DEI RISULTATI. Eur J Oncol. 2002;7(2):107-9. Notes: Q1? Q2? Q3? RET N25 BC TRZ? CHT? HT? MAB.
Bethune-Volters A, Guepratte S, Labroquere M, et al. Serum Her-2 marker, breast cancer and trastuzumab (Herceptine(registered trademark)): HER-2 SERIQUE, CANCER DU SEIN ET TRASTUZUMAB (HERCEPTINE(registered trademark)). Immuno-Anal Biol Spec. 2004;19(5 SPEC. ISS.):50-4. Notes: Q4 PRO N100 CHT TRZ ELS?.
Bethune-Volters A, Labroquere M, Guepratte S, et al. Longitudinal changes in serum HER-2/neu oncoprotein levels in trastuzumab-treated metastatic breast cancer patients. Anticancer Res. 2004;24(2C):1083-9. Notes: Q4 PRO N25 TRZ ELS?. [pmid: 15154627].
Beuzeboc P. [Indications for Herceptin in breast cancer treatment]. Gynecol Obstet Fertil. 2004;32(2):164-72. Notes: Q2? NRA?. [pmid: 15123142].
Bewick M, Chadderton T, Conlon M, et al. Expression of C-erbB-2/HER-2 in patients with metastatic breast cancer undergoing high-dose chemotherapy and autologous blood stem cell support. Bone Marrow Transplant. 1999;24(4):377-84. Notes: Q3A? Q4? N50 BC CHT ELS. [pmid: 10467326].
Bewick M, Conlon M, Gerard S, et al. HER-2 expression is a prognostic factor in patients with metastatic breast cancer treated with a combination of high-dose cyclophosphamide, mitoxantrone, paclitaxel and autologous blood stem cell support. Bone Marrow Transplant. 2001;27(8):847-53. Notes: Q4? RET? N25 BC CHT ELS. [pmid: 11477443].
Bewick M, Conlon M, Lee H, et al. Evaluation of sICAM-1, sVCAM-1, and sE-Selectin levels in patients with metastatic breast cancer receiving high-dose chemotherapy. Stem Cells Dev. 2004;13(3):281-94. Notes: Q4? RET? N50 BC CHT ELS. [pmid: 15186724].
Bewick M, Conlon M, Parissenti AM, et al. Soluble Fas (CD95) is a prognostic factor in patients with metastatic breast cancer undergoing high-dose chemotherapy and autologous stem cell transplantation. J Hematother Stem Cell Res. 2001;10(6):759-68. Notes: Q3A? Q4? RET? N50 BC CHT ELS. [pmid: 11798502].
Bigler LR, Streckfus CF, Copeland L, et al. The potential use of saliva to detect recurrence of disease in women with breast carcinoma. J Oral Pathol Med. 2002;31(7):421-31. Notes: Q4? PRO N25 O? T? ELS OBF (saliva). [pmid: 12165061].
Bitran JD, Samuels B, Trujillo Y, Klein L, Schroeder L, Martinec J. Her2/neu overexpression is associated with treatment failure in women with high-risk stage II and stage IIIA breast cancer (>10 involved lymph nodes) treated with high-dose chemotherapy and autologous hematopoietic progenitor cell support following standard-dose adjuvant chemotherapy. Clin Cancer Res. 1996;2(9):1509-13. Notes: Q3A? PRO? N25 BC CHT HDC HM?. [pmid: 9816327].
Blackwell KL, Dewhirst MW, Liotcheva V, et al. HER-2 gene amplification correlates with higher levels of angiogenesis and lower levels of hypoxia in primary breast tumors. Clin Cancer Res. 2004;10(12 Pt 1):4083-8. Notes: Q1? Q3A? RET N100 BC CHT HDC IHC FIS. [pmid: 15217943].
Bonnefoi H, Diebold-Berger S, Therasse P, et al. Locally advanced/inflammatory breast cancers treated with intensive epirubicin-based neoadjuvant chemotherapy: are there molecular markers in the primary tumour that predict for 5-year clinical outcome?. Ann Oncol. 2003;14(3):406-13. Notes: Q3A? RCT N100 BC CHT IHC. [pmid: 12598346].
Bozcuk H, Gumus A, Ozbilim G, et al. Cluster analysis of p-glycoprotein, c-erb-B2 and P53 in relation to tumor histology strongly indicates prognosis in patients with operable non-small cell lung cancer. Med Sci Monit. 2005;11(6):HY11-20. Notes: Q5 RET CS N50 LC. [pmid: 15917726].
Bozzetti C, Musolino A, Camisa R, et al. Evaluation of HER-2/neu amplification and other biological markers as predictors of response to neoadjuvant anthracycline-based chemotherapy in primary breast cancer: the role of anthracycline dose intensity. Am J Clin Oncol. 2006;29(2):171-7. Notes: Q3A? RET N100 BC CHT FIS. [pmid: 16601438].
Brandt B, Vogt U, Schlotter CM, et al. Prognostic relevance of aberrations in the erbB oncogenes from breast, ovarian, oral and lung cancers: double-differential polymerase chain reaction (ddPCR) for clinical diagnosis. Gene. 1995;159(1):35-42. Notes: Q5 RET CS N100 BC. [pmid: 7607571].
Breuer B, De Vivo I, Luo JC, et al. erbB-2 and myc oncoproteins in sera and tumors of breast cancer patients. Cancer Epidemiol Biomarkers Prev. 1994;3(1):63-6. Notes: Q4? QEX? N25 BC T? O? ELS?. [pmid: 7906981].
Breuer B, Luo JC, DeVivo I, et al. Detection of elevated c-erbB-2 oncoprotein in the serum and tissue in breast cancer. MED SCI RES. 1993;21(10):383-4. Notes: Q4?.
Breuer B, Smith S, Thor A, et al. ErbB-2 protein in sera and tumors of breast cancer patients. Breast Cancer Res Treat. 1998;49(3):261-70. Notes: Q4? D? N50 BC T? O? ELS?. [pmid: 9776510].
Brooks KR, To K, Joshi MB, et al. Measurement of chemoresistance markers in patients with stage III non-small cell lung cancer: a novel approach for patient selection. Ann Thorac Surg. 2003;76(1):187-93. discussion 193. Notes: Q5 CS N50 LC IHC. [pmid: 12842538].
Brufsky A, Lembersky B, Schiffman K, Lieberman G, Paton VE. Hormone receptor status does not affect the clinical benefit of trastuzumab therapy for patients with metastatic breast cancer. Clin Breast Cancer. 2005;6(3):247-52. Notes: Q2? Q3A? RET N100 BC TRZ CHT FIS. [pmid: 16137436].
Brustmann H. Expression of cellular apoptosis susceptibility protein in serous ovarian carcinoma: A clinicopathologic and immunohistochemical study. Gynecol Oncol. 2004;92(1):268-76. Notes: Q5 CS N25 OC IHC. [pmid: 14751170].
Buchholz TA, Huang EH, Berry D, et al. Her2/neu-positive disease does not increase risk of locoregional recurrence for patients treated with neoadjuvant doxorubicin-based chemotherapy, mastectomy, and radiotherapy. Int J Radiat Oncol Biol Phys. 2004;59(5):1337-42. Notes: Q3A? RCT BC N100 CHT IHC FIS. [pmid: 15275718].
Buller RE, Anderson B, Connor JP, Robinson R. Familial ovarian cancer. GYNECOL ONCOL. 1993;51(2):160-6. Notes: Q5 CS N25 OC. [pmid: 7903948].
Burstein HJ, Harris LN, Gelman R, et al. Preoperative therapy with trastuzumab and paclitaxel followed by sequential adjuvant doxorubicin/cyclophosphamide for HER2 overexpressing stage II or III breast cancer: a pilot study. J Clin Oncol. 2003;21(1):46-53. Notes: Q2A? Q3A? PII N25 BC TRZ CHT IHC only. [pmid: 12506169].
Burstein HJ, Harris LN, Marcom PK, et al. Trastuzumab and vinorelbine as first-line therapy for HER2-overexpressing metastatic breast cancer: multicenter phase II trial with clinical outcomes, analysis of serum tumor markers as predictive factors, and cardiac surveillance algorithm. J Clin Oncol. 2003;21(15):2889-95. Notes: Q1? Q3A? Q4? PII N50 BC TRZ CHT IHC FIS ELS?. [pmid: 12885806].
Burstein HJ, Kuter I, Campos SM, et al. Clinical activity of trastuzumab and vinorelbine in women with HER2-overexpressing metastatic breast cancer. J Clin Oncol. 2001;19(10):2722-30. Notes: Q2? Q3A? PRO N25 BC TRZ CHT IHC only. [pmid: 11352965].
Campos S, Hamid O, Seiden MV, et al. Multicenter, randomized phase II trial of oral CI-1033 for previously treated advanced ovarian cancer. J Clin Oncol. 2005;23(24):5597-604. Notes: Q5 PII N100 OC IHC. [pmid: 16110019].
Canoz O, Ozkan M, Arsav V, et al. The role of c-erbB-2 expression on the survival of patients with small-cell lung cancer. Lung. 2006;184(5):267-72. Notes: Q5 RET CS LC IHC. [pmid: 17235726].
Cappuzzo F, Bemis L, Varella-Garcia M. HER2 mutation and response to trastuzumab therapy in non-small-cell lung cancer. N Engl J Med. 2006;354(24):2619-21. Notes: Q5 D? LC. [pmid: 16775247].
Carbognani P, Tincani G, Crafa P, et al. Biological markers in non-small cell lung cancer. Retrospective study of 10 year follow-up after surgery. J Cardiovasc Surg (Torino). 2002;43(4):545-8. Notes: Q5 CS N50 LC IHC.
Cardoso F, Durbecq V, Larsimont D, et al. Correlation between complete response to anthracycline-based chemotherapy and topoisomerase II-alpha gene amplification and protein overexpression in locally advanced/metastatic breast cancer. Int J Oncol. 2004;24(1):201-9. Notes: Q3A? RET N50 BC CHT FIS. [pmid: 14654958].
Carlomagno C, Perrone F, Gallo C, et al. c-erb B2 overexpression decreases the benefit of adjuvant tamoxifen in early-stage breast cancer without axillary lymph node metastases. J Clin Oncol. 1996;14(10):2702-8. Notes: Q3B? RET? RCT? N100 BC HT IHC. [pmid: 8874330].
Carlson RW, Moench SJ, Hammond ME, et al. HER2 testing in breast cancer: NCCN Task Force report and recommendations. J Natl Compr Canc Netw. 2006;4(Suppl 3):S1-22. quiz S23–4. Notes: Q1? Q2? Q3? NRA? N? BC TRZ CHT IHC FIS CORPORATE NAME: NCCN HER2 Testing in Breast Cancer Task Force.
Carney WP. The emerging role of monitoring serum HER-2/neu oncoprotein levels in women with metastatic breast cancer. Lab Med. 2003;34(1):58-64. Notes: Q4? NRA? N? BC T? O? HM?.
Carney WP, Neumann R, Lipton A, Leitzel K, Ali S, Price CP. Monitoring the circulating levels of the HER2/neu oncoprotein in breast cancer. Clin Breast Cancer. 2004;5(2):105-16. Notes: Q4? NRA?. [pmid: 15245613].
Carney WP, Neumann R, Lipton A, Leitzel K, Ali S, Price CP. Potential clinical utility of serum HER-2/neu oncoprotein concentrations in patients with breast cancer. Clin Chem. 2003;49(10):1579-98. Notes: Q4? SR N? BC O? T? ELS. [pmid: 14500583].
Castellvi J, Garcia A, Rojo F, et al. Phosphorylated 4E binding protein 1: a hallmark of cell signaling that correlates with survival in ovarian cancer. Cancer. 2006;107(8):1801-11. Notes: Q5 CS N100 OC HM?. [pmid: 16983702].
Chan JK, Loizzi V, Magistris A, et al. Differences in prognostic molecular markers between women over and under 45 years of age with advanced ovarian cancer. Clin Cancer Res. 2004;10(24):8538-43. Notes: Q5 CS N50 OC HM?. [pmid: 15623636].
Chan KY, Cheung AN, Yip SP, Ko HH, Lai TW, Khoo US. Population-based case-control study of HER2 genetic polymorphism and breast cancer risk. J Natl Cancer Inst. 2002;94(20):1581-2. Notes: Q3 CCS N? BC. [pmid: 12381713].
Chang E, Lee A, Lee E, et al. HER-2/neu oncogene amplification by chromogenic in situ hybridization in 130 breast cancers using tissue microarray and clinical follow-up studies. J Korean Med Sci. 2004;19(3):390-6. Notes: Q1 Q2? Q3? DAC N100 CHT (anthracycline if IHC 2+ or 3+) IHC CIS. [pmid: 15201505].
Chearskul S, Sinlarat P, Bhothisuwan K, et al. Serum c-erbB-2 protein in breast cancer patients. J Med Assoc Thai. 2000;83(8):886-93. Notes: Q4 D? N50 BC T? ELS. [pmid: 10998842].
Chen IH, Chang JT, Liao CT, Wang HM, Hsieh LL, Cheng AJ. Prognostic significance of EGFR and Her-2 in oral cavity cancer in betel quid prevalent area cancer prognosis. Br J Cancer. 2003;89(4):681-6. Notes: Q5 CS N50 HNC ELS. [pmid: 12915878].
Cheng C, Wu YL, Gu LJ, et al. [Predicting efficacy of neoadjuvant cheomotherapy on resectable stage IIIA non-small cell lung cancer by multi-gene expressions]. Ai Zheng. 2005;24(7):846-9. Notes: Q5 RCT N50 LC HM?. [pmid: 16004813].
Cheung KL, Pinder SE, Paish C, et al. The role of blood tumor marker measurement (using a biochemical index score and c-erbB2) in directing chemotherapy in metastatic breast cancer. Int J Biol Markers. 2000;15(3):203-9. Notes: Q4? D? N25 BC CHT ELS?. [pmid: 11012094].
Cheung TH, Wong YF, Chung TK, Maimonis P, Chang AM. Clinical use of serum c-erbB-2 in patients with ovarian masses. Gynecol Obstet Invest. 1999;48(2):133-7. Notes: Q5 CS N50 OC ELS. [pmid: 10461006].
Cho KJ, Kim JY, Lee SS, Oh KK. Mucoepidermoid carcinoma of the salivary gland—a clinico-pathologic and immunohistochemical study for c-erbB-2 oncoprotein. J Korean Med Sci. 1997;12(6):499-504. Notes: Q5 CS N25 HNC HM?. [pmid: 9443087].
Christodoulou C, Klouvas G, Pateli A, Mellou S, Sgouros J, Skarlos DV. Prolonged administration of weekly paclitaxel and trastuzumab in patients with advanced breast cancer. Anticancer Res. 2003;23(1B):737-44. Notes: Q2? PRO N25 BC TRZ CHT IHC. [pmid: 12680177].
Ciocca DR, Gago FE, Fanelli MA, Calderwood SK. Co-expression of steroid receptors (estrogen receptor alpha and/or progesterone receptors) and Her-2/neu: Clinical implications. J Steroid Biochem Mol Biol. 2006;102(15):32-40. Notes: Q3B? D? N? BC HT O? HM?. [pmid: 17049840].
Classen S, Kopp R, Possinger K, Weidenhagen R, Eiermann W, Wilmanns W. Clinical relevance of soluble c-erbB-2 for patients with metastatic breast cancer predicting the response to second-line hormone or chemotherapy. Tumour Biol. 2002;23(2):70-5. Notes: Q4? PRO? N50 BC HT CHT ELS?. [pmid: 12065844].
Climent MA, Segui MA, Peiro G, et al. Prognostic value of HER-2/neu and p53 expression in node-positive breast cancer. HER-2/neu effect on adjuvant tamoxifen treatment. Breast. 2001;10(1):67-77. Notes: Q3B? RET N100 BC HT IHC (HER2+ if ≥5% of cells had membrane staining). [pmid: 14965564].
Cobleigh MA, Vogel CL, Tripathy D, et al. Multinational study of the efficacy and safety of humanized anti-HER2 monoclonal antibody in women who have HER2-overexpressing metastatic breast cancer that has progressed after chemotherapy for metastatic disease. J Clin Oncol. 1999;17(9):2639-48. Notes: Q2? PRO N100 BC TRZ IHC. [pmid: 10561337].
Cocquyt VF, Schelfhout VR, Blondeel PN, et al. The role of biological markers as predictors of response to preoperative chemotherapy in large primary breast cancer. Med Oncol. 2003;20(3):221-31. Notes: Q3A PRO? N100 BC CHT IHC. [pmid: 14514971].
Colleoni M, Viale G, Zahrieh D, et al. Chemotherapy is more effective in patients with breast cancer not expressing steroid hormone receptors: a study of preoperative treatment. Clin Cancer Res. 2004;10(19):6622-8. Notes: Q3A RET N100 BC CHT IHC. [pmid: 15475452].
Concin N, Hefler L, van Bavel J, et al. Biological markers in pT1 and pT2 ovarian cancer with lymph node metastases. Gynecol Oncol. 2003;89(1):9-15. Notes: Q5 RET CS OC IHC. [pmid: 12694648].
Cook GB, Neaman IE, Goldblatt JL, et al. Clinical utility of serum HER-2/neu testing on the Bayer Immuno 1 automated system in breast cancer. Anticancer Res. 2001;21(2B):1465-70. Notes: Q4? D? N100 BC T? ELS. [pmid: 11396233].
Cooke T, Reeves J, Lanigan A, Stanton P. HER2 as a prognostic and predictive marker for breast cancer. Ann Oncol. 2001;12(Suppl 1):S23-8. Notes: Q1? Q3A? D? N? BC CHT OTH (ria). [pmid: 11521717].
Coon JS, Marcus E, Gupta-Burt S, et al. Amplification and overexpression of topoisomerase IIalpha predict response to anthracycline-based therapy in locally advanced breast cancer. Clin Cancer Res. 2002;8(4):1061-7. Notes: Q1? Q3A? RET? N25 BC CHT IHC FIS. [pmid: 11948114].
Corte MD, Rodil JA, Vazquez J, et al. Clinical significance of the quantitative assessment of the cytosolic concentration of HER-2/neu protein in breast cancer by immunoenzymatic assay (ELISA). J Cancer Res Clin Oncol. 2005;131(11):701-14. Notes: Q1? Q3A? Q3B? RET N100 BC CHT HT IHC ELS (cytosol extract). [pmid: 16075281].
Cox G, Jones JL, Andi A, Waller DA, O'Byrne KJ. A biological staging model for operable non-small cell lung cancer. Thorax. 2001;56(7):561-6. Notes: Q5 CS N100 LC IHC. [pmid: 11413356]. [pmcid: 1746096].
Craven JM, Pavelic ZP, Stambrook PJ, et al. Expression of c-erbB-2 gene in human head and neck carcinoma. Anticancer Res. 1992;12(6B):2273-6. Notes: Q5 CS N50 HNC IHC. [pmid: 1363518].
Cui F, Luo RC, Chen JZ, Chen B, Huang YX. [Therapeutic effect of TAX combined with Herceptin or epirubicin against breast cancer positive for Her-2/neu]. Di Yi Jun Yi Da Xue Xue Bao. 2005;25(12):1533-6. Notes: Q2? RCT? QEX? N50 TRZ CHT IHC. [pmid: 16361156].
D'Amico TA, Aloia TA, Moore MB, et al. Predicting the sites of metastases from lung cancer using molecular biologic markers. Ann Thorac Surg. 2001;72(4):1144-8. Notes: Q5 CS N100 LC IHC. [pmid: 11603427].
da Cruz Perez DE, Pires FR, Alves FA, Almeida OP, Kowalski LP. Salivary gland tumors in children and adolescents: a clinicopathologic and immunohistochemical study of fifty-three cases. Int J Pediatr Otorhinolaryngol. 2004;68(7):895-902. Notes: Q5 CS N50 HNC IHC. [pmid: 15183580].
Davidson B, Gotlieb WH, Ben-Baruch G, et al. E-Cadherin complex protein expression and survival in ovarian carcinoma. Gynecol Oncol. 2000;79(3):362-71. Notes: Q5 CS N50 OC IHC. [pmid: 11104606].
De Placido S, Perrone F, Carlomagno C, et al. CMF vs alternating CMF/EV in the adjuvant treatment of operable breast cancer. A single centre randomised clinical trial (Naples GUN-3 study). Br J Cancer. 1995;71(6):1283-7. [pmid: 7779724].
DeGrendele H. The anti-HER2 monoclonal antibody pertuzumab may be effective in androgen-independent prostate cancer. Clin Prostate Cancer. 2003;2(3):143-5. Notes: Q5 D? PC. [pmid: 15040856].
Del Fiol Manna E, Teixeira LC, Alvarenga M. Association between immunohistochemical expression of topoisomerase II(alpha), HER2 and hormone receptors and response to primary chemotherapy in breast cancer. Tumori. 2006;92(3):222-9. Notes: Q3A? RET N100 BC CHT HM?. [pmid: 16869240].
Delarue JC, Terrier P, Terrier-Lacombe MJ, Mouriesse H, Gotteland M, May-Levin F. Combined overexpression of c-erbB-2 protein and epidermal growth factor receptor (EGF-R) could be predictive of early and long-term outcome in human breast cancer: a pilot study. Bull Cancer. 1994;81(12):1067-77. Notes: Q3B? RET N50 BC HT IHC. [pmid: 7742595].
Depowski PL, Brien TP, Sheehan CE, Stylos S, Johnson RL, Ross JS. Prognostic significance of p34cdc2 cyclin-dependent kinase and MIB1 overexpression, and HER-2/neu gene amplification detected by fluorescence in situ hybridization in breast cancer. Am J Clin Pathol. 1999;112(4):459-69. Notes: Q3A? RET N100 BC CHT FIS. [pmid: 10510669].
Dhesy-Thind B, Pritchard KI, Messersmith H, O'malley F, Elavathil L, Trudeau M. HER2/neu in systemic therapy for women with breast cancer: a systematic review. Breast Cancer Res Treat 2007.
Di Leo A, Gancberg D, Larsimont D, et al. HER-2 amplification and topoisomerase IIalpha gene aberrations as predictive markers in node-positive breast cancer patients randomly treated either with an anthracycline-based therapy or with cyclophosphamide, methotrexate, and 5-fluorouracil. Clin Cancer Res. 2002;8(5):1107-16. Notes: Q3A RCT N100 BC CHT FIS. [pmid: 12006526].
Di Leo A, Larsimont D, Gancberg D, et al. HER-2 and topo-isomerase IIalpha as predictive markers in a population of node-positive breast cancer patients randomly treated with adjuvant CMF or epirubicin plus cyclophosphamide. Ann Oncol. 2001;12(8):1081-9. Notes: Q3A RCT N100 BC CHT MAB. [pmid: 11583189].
Diaconu C, Dogaru C, Iftime C, Dragomir C, Cozma L, Carasevici E. [Could biological aggressivity markers of breast cancer alter the therapeutic course? Preliminary results]. Rev Med Chir Soc Med Nat Iasi. 2002;107(2):334-7. Notes: Q3A? PRO PII? N50 BC CHT HM?. [pmid: 12638286].
Dicker AP, Rodeck U. Predicting the future from trials of the past: epidermal growth factor receptor expression and outcome of fractionated radiation therapy trials. J Clin Oncol. 2005;23(24):5437-9. Notes: Q5 NRA NPD HNC. [pmid: 16110005].
Diez M, Pollan M, Maestro M, et al. Prediction of recurrence by quantification of p185neu protein in non-small-cell lung cancer tissue. Br J Cancer. 1997;75(5):684-9. Notes: Q5 CS N50 LC ELS. [pmid: 9043025].
Ditsch N, Ruckert S, Kumper C, et al. Trastuzumab (Herceptin(registered trademark)): Monoclonal antibody in the treatment of HER2/neu-overexpressing breast cancer in the metastatic and (neo)adjuvant situation. Breast Care. 2006;1(2):78-84. Notes: NRA? Q2?.
Dittadi R, Zancan M, Perasole A, Gion M. Evaluation of HER-2/neu in serum and tissue of primary and metastatic breast cancer patients using an automated enzyme immunoassay. Int J Biol Markers. 2001;16(4):255-61. Notes: Q4 ADS? DAC? N100 BC T? O? ELS. [pmid: 11820721].
117 Dnistrian AM, Schwartz MK, Schwartz DC, Ghani F, Kish L. Significance of serum Her-2/neu oncoprotein, CA 15-3, and CEA in the clinical evaluation of metastatic breast cancer. J Clin Ligand Assay. 2002;25(2):215-20. Notes: Q4 PRO? N50 BC TRZ ELS.
Dowell J, Minna JD, Kirkpatrick P. Erlotinib hydrochloride. Nat Rev Drug Discov. 2005;4(1):13-4. Notes: Q5? NRA NPD LC. [pmid: 15690599].
Dowell JE, Minna JD. EGFR mutations and molecularly targeted therapy: a new era in the treatment of lung cancer. Nat Clin Pract Oncol. 2006;3(4):170-1. Notes: Q5 NRA NPD LC. [pmid: 16596125].
Dowsett M, Harper-Wynne C, Boeddinghaus I, et al. HER-2 amplification impedes the antiproliferative effects of hormone therapy in estrogen receptor-positive primary breast cancer. Cancer Res. 2001;61(23):8452-8. Notes: Q3B PRO D? N100 BC HT O? IHC FIS. [pmid: 11731427].
Dowsett M, Houghton J, Iden C, et al. Benefit from adjuvant tamoxifen therapy in primary breast cancer patients according oestrogen receptor, progesterone receptor, EGF receptor and HER2 status. Ann Oncol. 2006;17(5):818-26. Notes: Q3B RCT N100 BC HT IHC. [pmid: 16497822].
Dreilich M, Wanders A, Brattstrom D, et al. HER-2 overexpression (3+) in patients with squamous cell esophageal carcinoma correlates with poorer survival. Dis Esophagus. 2006;19(4):224-31. Notes: Q5 CS N50 HNC IHC. [pmid: 16866851].
Durbecq V, Paesmans M, Cardoso F, et al. Topoisomerase-II alpha expression as a predictive marker in a population of advanced breast cancer patients randomly treated either with single-agent doxorubicin or single-agent docetaxel. Mol Cancer Ther. 2004;3(10):1207-14. Notes: Q3A? RCT N100 BC CHT HM?. [pmid: 15486187].
Egawa C, Miyoshi Y, Takamura Y, Taguchi T, Tamaki Y, Noguchi S. Decreased expression of BRCA2 mRNA predicts favorable response to docetaxel in breast cancer. Int J Cancer. 2001;95(4):255-9. Notes: Q3A? PRO N25 BC CHT IHC. [pmid: 11400119].
Egawa C, Motomura K, Miyoshi Y, et al. Increased expression of BRCA1 mRNA predicts favorable response to anthracycline-containing chemotherapy in breast cancers. Breast Cancer Res Treat. 2003;78(1):45-50. Notes: Q3A? PRO N50 BC CHT IHC. [pmid: 12611456].
Elie C, Geay JF, Morcos M, et al. Lack of relationship between EGFR-1 immunohistochemical expression and prognosis in a multicentre clinical trial of 93 patients with advanced primary ovarian epithelial cancer (GINECO group). Br J Cancer. 2004;91(3):470-5. Notes: Q5 RET CS OC IHC. [pmid: 15226774].
Elkhuizen PHM, Van Slooten HJ, Clahsen PC, et al. High local recurrence risk after breast-conserving therapy in node- negative premenopausal breast cancer patients is greatly reduced by one course of perioperative chemotherapy: A European organization for research and treatment of cancer breast cancer cooperative group study. J Clin Oncol. 2000;18(5):1075-83. Notes: Q3A? RCT PRG N? BC CHT HM?. [pmid: 10694560].
Elkin EB, Weinstein MC, Winer EP, Kuntz KM, Schnitt SJ, Weeks JC. HER-2 testing and trastuzumab therapy for metastatic breast cancer: a cost-effectiveness analysis. J Clin Oncol. 2004;22(5):854-63. Notes: Q1? Q2? CEA N? BC TRZ CHT IHC FIS. [pmid: 14990641].
Elledge RM, Green S, Ciocca D, et al. HER-2 expression and response to tamoxifen in estrogen receptor-positive breast cancer: a Southwest Oncology Group Study. Clin Cancer Res. 1998;4(1):7-12. Notes: Q3B PRO N100 BC HT IHC. [pmid: 9516946].
Ellis MJ, Coop A, Singh B, et al. Letrozole is more effective neoadjuvant endocrine therapy than tamoxifen for ErbB-1- and/or ErbB-2-positive, estrogen receptor-positive primary breast cancer: evidence from a phase III randomized trial. J Clin Oncol. 2001;19(18):3808-16. Notes: Q3B RCT N? BC HT IHC. [pmid: 11559718].
Ellis MJ, Coop A, Singh B, et al. Letrozole inhibits tumor proliferation more effectively than tamoxifen independent of HER1/2 expression status. Cancer Res. 2003;63(19):6523-31. Notes: Q3B RCT N100 BC HT IHC. [pmid: 14559846].
Ellis MJ, Tao Y, Young O, et al. Estrogen-independent proliferation is present in estrogen-receptor HER2-positive primary breast cancer after neoadjuvant letrozole. J Clin Oncol. 2006;24(19):3019-25. Notes: Q1? Q3B? PRO? N100 BC HT IHC FIS. [pmid: 16754938].
Eskelinen M, Kataja V, Hamalainen E, Kosma VM, Penttila I, Alhava E. Serum tumour markers CEA, AFP, CA 15-3, TPS and Neu in diagnosis of breast cancer. Anticancer Res. 1997;17(2B):1231-4. Notes: Q4? PRO N100 BC T? O? HM?. [pmid: 9137478].
Esslimani-Sahla M, Simony-Lafontaine J, Kramar A, et al. Estrogen receptor beta (ER beta) level but not its ER beta cx variant helps to predict tamoxifen resistance in breast cancer. Clin Cancer Res. 2004;10(17):5769-76. Notes: Q3B RET N50 BC HT IHC. [pmid: 15355905].
Esteva FJ, Cheli CD, Fritsche H, et al. Clinical utility of serum HER2/neu in monitoring and prediction of progression-free survival in metastatic breast cancer patients treated with trastuzumab-based therapies. Breast Cancer Res. 2005;7(4):R436-43. Notes: Q4 RET? N100 BC TRZ ELS. [pmid: 15987448].
Esteva FJ, Valero V, Booser D, et al. Phase II study of weekly docetaxel and trastuzumab for patients with HER-2-overexpressing metastatic breast cancer. J Clin Oncol. 2002;20(7):1800-8. Notes: Q2? Q4? PII N25 BC TRZ CHT FIS ELS. [pmid: 11919237].
Fabi A, Ferretti G, Salesi N, et al. Can HER2 overexpression predict response to pegylated liposomal doxorubicin in metastatic breast cancer patients? [4]. Ann Oncol. 2005;16(3):516-7. Notes: Q3A?. [pmid: 15642705].
Farmer G. Targeted lung cancer therapies. Nat Rev Drug Discov. 2004;3(7):547-8. Notes: Q5? NRA NPD LC. [pmid: 15272497].
Fehm T, Gebauer G, Jager W. Clinical utility of serial serum c-erbB-2 determinations in the follow-up of breast cancer patients. Breast Cancer Res Treat. 2002;75(2):97-106. Notes: Q4 RET N50 BC T? ELS. [pmid: 12243512].
Fehm T, Jager W, Kraemer S, et al. Changes of serum HER2 status during clinical course of metastatic breast cancer patients. Anticancer Res. 2004;24(6):4205-10. Notes: Q4 RET N100 BC T? ELS. [pmid: 15739264].
Fehm T, Jager W, Kramer S, et al. Prognostic significance of serum HER2 and CA 15-3 at the time of diagnosis of metastatic breast cancer. Anticancer Res. 2004;24(3b):1987-92. Notes: Q4 D? N100 BC T? O? ELS?. [pmid: 15274389].
Fehm T, Maimonis P, Katalinic A, Jager WH. The prognostic significance of c-erbB-2 serum protein in metastatic breast cancer. Oncology. 1998;55(1):33-8. Notes: Q4 RET PRG? N50 BC CHT ELS. [pmid: 9428373].
Fehm T, Maimonis P, Weitz S, Teramoto Y, Katalinic A, Jager W. Influence of circulating c-erbB-2 serum protein on response to adjuvant chemotherapy in node-positive breast cancer patients. Breast Cancer Res Treat. 1997;43(1):87-95. Notes: Q4 RET QEX N100 BC CHT ELS. [pmid: 9065602].
Felix A, El-Naggar AK, Press MF, et al. Prognostic significance of biomarkers (c-erbB-2, p53, proliferating cell nuclear antigen, and DNA content) in salivary duct carcinoma. HUM PATHOL. 1996;27(6):561-6. Notes: Q5 CS N25 HNC HM?. [pmid: 8666365].
Fernandez Acenero MJ, Farina Gonzalez J, Arangoncillo Ballesteros P. Immunohistochemical expression of p53 and c-erbB-2 in breast carcinoma: relation with epidemiologic factors, histologic features and prognosis. Gen Diagn Pathol. 1997;142(56):289-96. Notes: Q3A? RET N100 BC CHT IT? IHC. [pmid: 9228251].
Fernandez-Sanchez M, Gamboa-Dominguez A, Uribe N, et al. Clinical and pathological predictors of the response to neoadjuvant anthracycline chemotherapy in locally advanced breast cancer. Med Oncol. 2006;23(2):171-83. Notes: Q3A RET N25 BC CHT IHC (only 3+ considered HER2+). [pmid: 16720917].
Ferrari S, Bertoni F, Zanella L, et al. Evaluation of P-glycoprotein, HER-2/ErbB-2, p53, and Bcl-2 in primary tumor and metachronous lung metastases in patients with high-grade osteosarcoma. Cancer. 2004;100(9):1936-42. Notes: Q5 CS FEW LC HM?. [pmid: 15112275].
Field JK, Spandidos DA, Yiagnisis M, Gosney JR, Papadimitriou K, Stell PM. C-erbB-2 expression in squamous cell carcinoma of the head and neck. Anticancer Res. 1992;12(3):613-9. Notes: Q5 CS N50 HNC IHC. [pmid: 1377893].
Filiberti R, Marroni P, Paganuzzi M, et al. c-erbB-2 protein in serum of primary lung cancer patients. Cancer Detect Prev. 2002;26(1):64-8. Notes: Q5 CS N50 LC HM?. [pmid: 12088205].
Fleming MV, Guinee DG Jr, Chu WS, et al. Bcl-2 immunohistochemistry in a surgical series of non-small cell lung cancer patients. Hum Pathol. 1998;29(1):60-4. Notes: Q5 CS N100 LC IHC. [pmid: 9445135].
Fonseca FL, Soares HP, Manhani AR, et al. Peripheral blood c-erbB-2 expression by reverse transcriptase-polymerase chain reaction in breast cancer patients receiving chemotherapy. Clin Breast Cancer. 2002;3(3):201-5. Notes: Q4? D? FEW BC T? O? RNA CTC. [pmid: 12196278].
Fonseca GN, Srougi M, Leite KR, Nesrallah LJ, Ortiz V. The role of HER2/neu, BCL2, p53 genes and proliferating cell nuclear protein as molecular prognostic parameters in localized prostate carcinoma. Sao Paulo Med J. 2004;122(3):124-7. Notes: Q5 CS N100 PC IHC. [pmid: 15448811].
Fontana X, Ferrari P, Namer M, Peysson R, Salanon C, Bussiere F. C-erb-B2 gene amplification and serum level of c-erb-B2 oncoprotein at primary breast cancer diagnosis. Anticancer Res. 1994;14(5B):2099-104. Notes: Q4 RET N100 BC T? O? HM? ELS?. [pmid: 7840506].
Formenti SC, Dunnington G, Uzieli B, et al. Original p53 status predicts for pathological response in locally advanced breast cancer patients treated preoperatively with continuous infusion 5-fluorouracil and radiation therapy. Int J Radiat Oncol Biol Phys. 1997;39(5):1059-68. Notes: Q3A? PRO N25 BC CHT (RTx) IHC. [pmid: 9392545].
Formenti SC, Spicer D, Skinner K, et al. Low HER2/neu gene expression is associated with pathological response to concurrent paclitaxel and radiation therapy in locally advanced breast cancer. Int J Radiat Oncol Biol Phys. 2002;52(2):397-405. Notes: Q1? Q3A PRO N25 BC CHT (+RTx) IHC PCR. [pmid: 11872285].
Fornier M, Risio M, Van Poznak C, Seidman A. HER2 testing and correlation with efficacy of trastuzumab therapy. Oncology (Williston Park). 2002;16(10):1340-8. 1351–2; discussion 1352, 1355–8. Notes: Q1? Q2? NRA?. [pmid: 12435204].
Fountzilas G, Tsavdaridis D, Kalogera-Fountzila A, et al. Weekly paclitaxel as first-line chemotherapy and trastuzumab in patients with advanced breast cancer. A Hellenic Cooperative Oncology Group phase II study. Ann Oncol. 2001;12(11):1545-51. Notes: Q2? Q3A? PRO N25 BC TRZ CHT IHC. [pmid: 11822753].
Franchi A, Gallo O, Boddi V, Santucci M. Prediction of occult neck metastases in laryngeal carcinoma: role of proliferating cell nuclear antigen, MIB-1, and E-cadherin immunohistochemical determination. Clin Cancer Res. 1996;2(10):1801-8. Notes: Q5 CS N25 HNC IHC. [pmid: 9816133].
Francis G, Beadle G, Thomas S, Mengersen K, Stein S. Evaluation of oestrogen and progesterone receptor status in HER-2 positive breast carcinomas and correlation with outcome. Pathology (Phila). 2006;38(5):391-8. Notes: Q1? Q3B? RET N100 BC HT MAB.
Frank JL, Garb JL, Banson BB, et al. Epidermal growth factor receptor expression in squamous cell carcinoma of the hypopharynx. SURG ONCOL. 1993;2(3):161-7. Notes: Q5 RET CS HNC IT?. [pmid: 8252205].
Freudenberg LS, Sheu S, Gorges R et al. Prognostic value of c-erbB-2 expression in papillary thyroid carcinoma. Nuklearmedizin 2005; 44(5):179–82, 184. Notes: Q5 CS N25 HNC IHC
Friess H, Fukuda A, Tang WH, et al. Concomitant analysis of the epidermal growth factor receptor family in esophageal cancer: overexpression of epidermal growth factor receptor mRNA but not of c-erbB-2 and c-erbB-3. World J Surg. 1999;23(10):1010-8. Notes: Q5 CS N25 HNC IHC NB. [pmid: 10512940].
Frisch SM. E1A as a tumor suppressor gene: commentary re S. Madhusudan et al. A multicenter Phase I gene therapy clinical trial involving intraperitoneal administration of E1A-lipid complex in patients with recurrent epithelial ovarian cancer overexpressing HER-2/neu oncogene. Clin Cancer Res. 2004;10(9):2905-7. Notes: Q5 PI N? OC. [pmid: 15131023].
Fritz P, Cabrera CM, Dippon J, et al. c-erbB2 and topoisomerase IIalpha protein expression independently predict poor survival in primary human breast cancer: a retrospective study. Breast Cancer Res. 2005;7(3):R374-84. Notes: Q3A? RET N100 BC CHT IHC. [pmid: 15987433].
Frutuoso C, Silva MR, Amaral N, Martins I, De Oliveira C, De Oliveira HM. [Prognosis value of p53, C-erB-2 and Ki67 proteins in ovarian carcinoma]. Acta Med Port. 2001;14(3):277-83. Notes: Q5 CS N50 OC IHC. [pmid: 11552325].
Gadducci A, Ciancia EM, Campani D, et al. Immunohistochemical detection of p185 product, p21 product, and proliferating cell nuclear antigen (PCNA) in formalin-fixed, paraffin-embedded tissues from ovarian carcinomas. Preliminary data. Eur J Gynaecol Oncol. 1994;15(5):359-68. Notes: Q5 CS N25 OC IHC. [pmid: 7828605].
Gago FE, Fanelli MA, Ciocca DR. Co-expression of steroid hormone receptors (estrogen receptor alpha and/or progesterone receptors) and Her2/neu (c-erbB-2) in breast cancer: clinical outcome following tamoxifen-based adjuvant therapy. J Steroid Biochem Mol Biol. 2006;98(1):36-40. Notes: Q3B PRO N50 BC HT (adjuvant) HM?. [pmid: 16188438].
Gallo O, Franchi A, Fini-Storchi I, et al. Prognostic significance of c-erbB-2 oncoprotein expression in intestinal-type adenocarcinoma of the sinonasal tract. Head Neck. 1998;20(3):224-31. Notes: Q5 CS N25 HNC IHC. [pmid: 9570628].
Gasparini G, Sarmiento R, Amici S, et al. Gefitinib (ZD1839) combined with weekly epirubicin in patients with metastatic breast cancer: a phase I study with biological correlate. Ann Oncol. 2005;16(12):1867-73. Notes: Q4? PRO FEW BC CHT HM? (ELS?). [pmid: 16107496].
Gee JM, Robertson JF, Gutteridge E, et al. Epidermal growth factor receptor/HER2/insulin-like growth factor receptor signalling and oestrogen receptor activity in clinical breast cancer. Endocr-Relat Cancer. 2005;12(SUPPL. 1):S99-S111. Notes: Q3B? RET PRG N? BC HT HM?. [pmid: 16113104].
Geisler S, Lonning PE, Aas T, et al. Influence of TP53 gene alterations and c-erbB-2 expression on the response to treatment with doxorubicin in locally advanced breast cancer. Cancer Res. 2001;61(6):2505-12. Notes: Q3A D? N50 BC CHT HM?. [pmid: 11289122].
Generali D, Fox SB, Berruti A, et al. Role of carbonic anhydrase IX expression in prediction of the efficacy and outcome of primary epirubicin/tamoxifen therapy for breast cancer. Endocr Relat Cancer. 2006;13(3):921-30. Notes: Q3? RCT N100 BC CHT HT IHC only. [pmid: 16954440].
Gershenson DM, Baker VV, Price JE, et al. Molecular profile of advanced-stage transitional cell carcinoma of the ovary. Am J Obstet Gynecol. 1997;177(1):120-5. Notes: Q5 CS N25 OC IHC. [pmid: 9240594].
Giannoni C, el-Naggar AK, Ordonez NG, et al. c-erbB-2/neu oncogene and Ki-67 analysis in the assessment of palatal salivary gland neoplasms. Otolaryngol Head Neck Surg. 1995;112(3):391-8. Notes: Q5 CS N50 HNC HM?. [pmid: 7870438].
Giatromanolaki A, Koukourakis MI, Sivridis E, Fountzilas G. c-erbB-2 oncoprotein is overexpressed in poorly vascularised squamous cell carcinomas of the head and neck, but is not associated with response to cytotoxic therapy or survival. Anticancer Res. 2000;20(2A):997-1004. Notes: Q5 CS N50 HNC HM?. [pmid: 10810387].
Gibault L, Metges JP, Conan-Charlet V, et al. Diffuse EGFR staining is associated with reduced overall survival in locally advanced oesophageal squamous cell cancer. Br J Cancer. 2005;93(1):107-15. Notes: Q5 CS N100 HNC IHC. [pmid: 15986037].
Goff BA, Muntz HG, Greer BE, Tamimi HK, Gown AM. Oncogene expression: long-term compared with short-term survival in patients with advanced epithelial ovarian cancer. Obstet Gynecol. 1998;92(1):88-93. Notes: Q5 CS FEW OC IHC. [pmid: 9649100].
Gonzalez-Angulo AM, Broglio K, Kau SW, et al. Women age < 35 years with primary breast carcinoma: Disease features at presentation. Cancer. 2005;103(12):2466-72. Notes: Q5 CS N100 BC. [pmid: 15852360].
Gonzalez-Angulo AM, Krishnamurthy S, Yamamura Y, et al. Lack of association between amplification of her-2 and response to preoperative taxanes in patients with breast carcinoma. Cancer. 2004;101(2):258-63. Notes: Q3A? D? N50 BC CHT FIS. [pmid: 15241821].
Goodell V, Salazar LG, Urban N, et al. Antibody immunity to the p53 oncogenic protein is a prognostic indicator in ovarian cancer. J Clin Oncol. 2006;24(5):762-8. Notes: Q5 CS N100 OC ELS. [pmid: 16391298].
Goodin S. Erlotinib: optimizing therapy with predictors of response?. Clin Cancer Res. 2006;12(10):2961-3. Notes: Q5? D? LC. [pmid: 16707589].
Gordon MS, Matei D, Aghajanian C, et al. Clinical activity of pertuzumab (rhuMAb 2C4), a HER dimerization inhibitor, in advanced ovarian cancer: potential predictive relationship with tumor HER2 activation status. J Clin Oncol. 2006;24(26):4324-32. Notes: Q5 PII N50 OC HM?. [pmid: 16896006].
Green JA, Berns EM, Coens C, et al. Alterations in the p53 pathway and prognosis in advanced ovarian cancer: a multi-factorial analysis of the EORTC Gynaecological Cancer group (study 55865). Eur J Cancer. 2006;42(15):2539-48. Notes: Q5 RCT N100 OC IHC. [pmid: 16965910].
Gregory RK, Powles TJ, Salter J, Chang JC, Ashley S, Dowsett M. Prognostic relevance of cerbB2 expression following neoadjuvant chemotherapy in patients in a randomised trial of neoadjuvant versus adjuvant chemoendocrine therapy. Breast Cancer Res Treat. 2000;59(2):171-5. Notes: Q3A? RCT N100 BC CHT HT IHC. [pmid: 10817352].
Guarneri V, Bengala C, Orlandini C, et al. HER2 overexpression as a prognostic factor in metastatic breast cancer patients treated with high-dose chemotherapy and autologous stem cell support. Bone Marrow Transplant. 2004;34(5):413-7. Notes: Q3A? HDC RET N25 BC CHT IHC. [pmid: 15273709].
Guerry M, Vabre L, Talbot M, et al. Prognostic value of histological and biological markers in pharyngeal squamous cell carcinoma: a case-control study. Br J Cancer. 1998;77(11):1932-6. Notes: Q5 PRG N25 HNC. [pmid: 9667670].
Gupta AK, Soto DE, Feldman MD, et al. Signaling pathways in NSCLC as a predictor of outcome and response to therapy. Lung. 2004;182(3):151-62. Notes: Q5 CS N25 LC IHC. [pmid: 15526754].
Gutierrez MC, Detre S, Johnston S, et al. Molecular changes in tamoxifen-resistant breast cancer: relationship between estrogen receptor, HER-2, and p38 mitogen-activated protein kinase. J Clin Oncol. 2005;23(11):2469-76. Notes: Q3B? RET? N25 BC HT HM?. [pmid: 15753463].
Haddad R, Colevas AD, Krane JF, et al. Herceptin in patients with advanced or metastatic salivary gland carcinomas. A phase II study. Oral Oncol. 2003;39(7):724-7. Notes: Q5 PII FEW HNC. [pmid: 12907212].
Hait WN. The prognostic and predictive values of ECD-HER-2. Clin Cancer Res. 2001;7(9):2601-4. Notes: Q4? RET N100 BC CHT HT ELS. [pmid: 11555568].
Halperin R, Zehavi S, Hadas E, Habler L, Bukovsky I, Schneider D. Immunohistochemical comparison of primary peritoneal and primary ovarian serous papillary carcinoma. Int J Gynecol Pathol. 2001;20(4):341-5. Notes: Q5 CS N25 OC IHC. [pmid: 11603217].
Hamid O. Emerging treatments in oncology: focus on tyrosine kinase (erbB) receptor inhibitors. J Am Pharm Assoc (Wash DC). 2004;44(1):52-8. Notes: Q3AB Q4 Q5 SR BC.
Hamilton A, Larsimont D, Paridaens R, et al. A study of the value of p53, HER2, and Bcl-2 in the prediction of response to doxorubicin and paclitaxel as single agents in metastatic breast cancer: a companion study to EORTC 10923. Clin Breast Cancer. 2000;1(3):233-40. discussion 241–2. Notes: Q3A? RCT? N100 BC CHT IHC. [pmid: 11899648].
Hannemann J, Kristel P, van Tinteren H, et al. Molecular subtypes of breast cancer and amplification of topoisomerase II alpha: predictive role in dose intensive adjuvant chemotherapy. Br J Cancer. 2006;95(10):1334-41. Notes: Q3A? RCT? N100 BC CHT IHC?. [pmid: 17088909].
Harpole DH Jr, Herndon JE 2nd, Wolfe WG, Iglehart JD, Marks JR. A prognostic model of recurrence and death in stage I non-small cell lung cancer utilizing presentation, histopathology, and oncoprotein expression. Cancer Res. 1995;55(1):51-6. Notes: Q5 CS N100 LC IHC. [pmid: 7805040].
Harpole DH Jr, Marks JR, Richards WG, Herndon JE 2nd, Sugarbaker DJ. Localized adenocarcinoma of the lung: oncogene expression of erbB-2 and p53 in 150 patients. Clin Cancer Res. 1995;1(6):659-64. Notes: Q5 CS N100 LC IHC. [pmid: 9816029].
Harris L, Luftner D, Jager W, Robertson JF. c-erbB-2 in serum of patients with breast cancer. Int J Biol Markers. 1999;14(1):8-15. Notes: NRA? Q4? D? N? BC T? O? ELS?. [pmid: 10367244].
Harris LN, Liotcheva V, Broadwater G, et al. Comparison of methods of measuring HER-2 in metastatic breast cancer patients treated with high-dose chemotherapy. J Clin Oncol. 2001;19(6):1698-706. Notes: Q1? Q3A? Q4? PRO? N100 BC CHT IHC FIS ELS. [pmid: 11250999].
Hartmann LC, Ingle JN, Wold LE, et al. Prognostic value of c-erbB2 overexpression in axillary lymph node positive breast cancer: Results from a randomized adjuvant treatment protocol. Cancer. 1994;74(11):2956-63. Notes: Q3A? PRO? N100 BC CHT IHC. [pmid: 7954259].
Hayes DF. Is there a role for monitoring circulating HER2?. Clin Breast Cancer. 2002;3(2):136-7. Notes: Q4?.
Hayes DF, Yamauchi H, Broadwater G, et al. Circulating HER-2/erbB-2/c-neu (HER-2) extracellular domain as a prognostic factor in patients with metastatic breast cancer: Cancer and Leukemia Group B Study 8662. Clin Cancer Res. 2001;7(9):2703-11. Notes: Q4? RET N100 BC CHT HT ELS CORPORATE NAME: Cancer and Leukemia Group B. [pmid: 11555582].
Held-Warmkessel J. Emerging therapies in head and neck cancers: EGFR inhibitors. ONS News. 2006;21(8 Suppl):61-2. Notes: Q5? NRA NPD HNC. [pmid: 16925156].
Herbst RS, Hong WK. Targeted therapy against the epidermal growth factor receptor: Introduction. Semin Oncol. 2002;29(5 SUPPL. 14):1-2. Notes: Q5? NRA NPD HNC.
Hernes E, Fossa SD, Berner A, Otnes B, Nesland JM. Expression of the epidermal growth factor receptor family in prostate carcinoma before and during androgen-independence. Br J Cancer. 2004;90(2):449-54. Notes: Q5 CS N100 PC IHC. [pmid: 14735192].
Hicks DG, Yoder BJ, Pettay J, et al. The incidence of topoisomerase II-alpha genomic alterations in adenocarcinoma of the breast and their relationship to human epidermal growth factor receptor-2 gene amplification: a fluorescence in situ hybridization study. Hum Pathol. 2005;36(4):348-56. Notes: Q3A? RET N100 BC CHT? FIS. [pmid: 15891995].
Hidalgo M, Siu LL, Nemunaitis J, et al. Phase I and pharmacologic study of OSI-774, an epidermal growth factor receptor tyrosine kinase inhibitor, in patients with advanced solid malignancies. J Clin Oncol. 2001;19(13):3267-79. Notes: Q5? PI N? D?. [pmid: 11432895].
Hilbe W, Dirnhofer S, Oberwasserlechner F, et al. Immunohistochemical typing of non-small cell lung cancer on cryostat sections: correlation with clinical parameters and prognosis. J Clin Pathol. 2003;56(10):736-41. Notes: Q5 CS N50 LC IHC. [pmid: 14514775]. [pmcid: 1770084].
Hirschowitz EA, Foody T, Kryscio R, Dickson L, Sturgill J, Yannelli J. Autologous dendritic cell vaccines for non-small-cell lung cancer. J Clin Oncol. 2004;22(14):2808-15. Notes: Q5 CS FEW LC HM?. [pmid: 15254048].
Hogdall EV, Christensen L, Kjaer SK, et al. Distribution of HER-2 overexpression in ovarian carcinoma tissue and its prognostic value in patients with ovarian carcinoma: from the Danish MALOVA Ovarian Cancer Study. Cancer. 2003;98(1):66-73. Notes: Q5 PRO CS N100 OC HM?. [pmid: 12833457].
Hoopmann M, Neumann R, Tanasale T, Schondorf T. HER-2/neu determination in blood plasma of patients with HER-2/neu overexpressing metastasized breast cancer: a longitudinal study. Anticancer Res. 2003;23(2A):1031-4. Notes: Q4? RET FEW BC TRZ ELS. [pmid: 12820343].
Horiguchi J, Koibuchi Y, Iijima K, et al. Co-expressed type of ER and HER2 protein as a predictive factor in determining resistance to antiestrogen therapy in patients with ER-positive and HER2-positive breast cancer. Oncol Rep. 2005;14(5):1109-16. Notes: Q3B? RET N100 BC HT (adjuvant) IHC. [pmid: 16211272].
Horiguchi J, Koibuchi Y, Iijima K, et al. Immunohistochemical double staining with estrogen receptor and HER2 on primary breast cancer. Int J Mol Med. 2003;12(6):855-9. Notes: Q3B? RET N100 BC HT IHC. [pmid: 14612957].
Hornung R, Urs E, Serenella E, et al. Analysis of potential prognostic factors in 111 patients with ovarian cancer. Cancer Lett. 2004;206(1):97-106. Notes: Q5 CS N100 OC HM?. [pmid: 15019165].
Hosono M, Saga T, Sakahara H, et al. Construction of immunoradiometric assay for circulating c-erbB-2 protooncogene product in advanced breast cancer patients. Jpn J Cancer Res. 1993;84(2):147-52. Notes: Q4? D? FEW BC T? O? ELS. [pmid: 8096502].
Houston SJ, Plunkett TA, Barnes DM, Smith P, Rubens RD, Miles DW. Overexpression of c-erbB2 is an independent marker of resistance to endocrine therapy in advanced breast cancer. Br J Cancer. 1999;79(78):1220-6. Notes: Q3B? RET N100 BC HT IHC. [pmid: 10098763].
Hruza C, Dobianer K, Beck A, et al. HER-2 and INT-2 amplification estimated by quantitative PCR in paraffin-embedded ovarian cancer tissue samples. Eur J Cancer. 1993;29A(11):1593-7. Notes: Q5 CS N100 OC PCR. [pmid: 8105839].
Hsu YH, Shaw CK. The DCC protein expression in breast carcinoma. Kaohsiung J Med Sci. 2000;16(5):233-40. Notes: Q3? RET PRG? N50 BC T? IHC. [pmid: 10969518].
Hu JC, Mokbel K. Does c-erbB2/HER2 overexpression predict adjuvant tamoxifen failure in patients with early breast cancer?. Eur J Surg Oncol. 2001;27(4):335-7. Notes: Q3B?. [pmid: 11417974].
Huang HJ, Neven P, Drijkoningen M, et al. Association between HER-2/neu and the progesterone receptor in oestrogen-dependent breast cancer is age-related. Breast Cancer Res Treat. 2005;91(1):81-7. Notes: Q3B? RET? N100 BC T? O? IHC. [pmid: 15868434].
Hudelist G, Kostler W, Czerwenka K, Kubista E, Singer CF. Predicting the clinical course of breast cancer patients undergoing trastuzumab-based therapy: an outlook. Methods Find Exp Clin Pharmacol. 2004;26(3):201-10. Notes: Q2? NRA. [pmid: 15148526].
Hudelist G, Kostler WJ, Attems J, et al. Her-2/neu-triggered intracellular tyrosine kinase activation: in vivo relevance of ligand-independent activation mechanisms and impact upon the efficacy of trastuzumab-based treatment. Br J Cancer. 2003;89(6):983-91. Notes: Q2? Q4? PRO? N50 BC TRZ ELS IHC FIS. [pmid: 12966413].
Hudelist G, Kostler WJ, Czerwenka K, et al. Her-2/neu and EGFR tyrosine kinase activation predict the efficacy of trastuzumab-based therapy in patients with metastatic breast cancer. Int J Cancer. 2006;118(5):1126-34. Notes: Q2? RET N25 BC TRZ IHC. [pmid: 16161043].
Hudelist G, Kostler WJ, Gschwantler-Kaulich D, et al. Serum EGFR levels and efficacy of trastuzumab-based therapy in patients with metastatic breast cancer. Eur J Cancer. 2006;42(2):186-92. Notes: Q4? PRO? N25 BC TRZ ELS. [pmid: 16326100].
Hudis CA. Trastuzumab adds to adjuvant chemotherapy for resected HER2-positive breast cancer. Nat Clin Pract Oncol. 2006;3(1):12-3. Notes: Q2? NRA?. [pmid: 16407871].
Hueman MT, Dehqanzada ZA, Novak TE, et al. Phase I clinical trial of a HER-2/neu peptide (E75) vaccine for the prevention of prostate-specific antigen recurrence in high-risk prostate cancer patients. Clin Cancer Res. 2005;11(20):7470-9. Notes: Q5 PI N50 PC HM?. [pmid: 16243821].
Hurley J, Doliny P, Reis I, et al. Docetaxel, cisplatin, and trastuzumab as primary systemic therapy for human epidermal growth factor receptor 2-positive locally advanced breast cancer. J Clin Oncol. 2006;24(12):1831-8. Notes: Q1? Q2? Q3A? PRO N25 BC TRZ CHT IHC FIS. [pmid: 16549824].
HWu JT. C-erbB2 oncoprotein and its soluble ectodomain: a new potential tumor marker for prognosis early detection and monitoring patients undergoing Herceptin treatment. Clin Chim Acta. 2002;322(12):11-9. Notes: Q4? NRA. [pmid: 12104076].
Ibrahim SO, Vasstrand EN, Liavaag PG, Johannessen AC, Lillehaug JR. Expression of c-erbB proto-oncogene family members in squamous cell carcinoma of the head and neck. Anticancer Res. 1997;17(6D):4539-46. Notes: Q5 CS FEW HNC IHC. [pmid: 9494565].
Imoto S, Kitoh T, Hasebe T. Serum c-erB-2 levels in monitoring of operable breast cancer patients. Jpn J Clin Oncol. 1999;29(7):336-9. Notes: Q4? PRO N100 BC T? ELS. [pmid: 10470658].
Isola JJ, Holli K, Oksa H, Teramoto Y, Kallioniemi OP. Elevated erbB-2 oncoprotein levels in preoperative and follow-up serum samples define an aggressive disease course in patients with breast cancer. Cancer. 1994;73(3):652-8. Notes: Q4? PRO? N100 BC T? ELS IHC. [pmid: 7905363].
Issing WJ, Dreps A, Heppt WJ, Wustrow TP, Riederer A, Zagury JF. erbB-2/Her-2 gene amplification and overexpression in parotid gland tumors. Eur Arch Otorhinolaryngol. 1993;250(3):150-3. Notes: Q5 CS FEW HNC. [pmid: 8102855].
Jacot W, Pujol JL, Boher JM, Lamy PJ. Serum EGF-receptor and HER-2 extracellular domains and prognosis of non-small-cell lung cancer. Br J Cancer. 2004;91(3):430-3. Notes: Q5 CS N100 LC ELS. [pmid: 15226769].
Jacquemier J, Penault-Llorca F, Viens P, et al. Breast cancer response to adjuvant chemotherapy in correlation with erbB2 and p53 expression. Anticancer Res. 1994;14(6B):2773-8. Notes: Q3A RET N50 BC CHT IHC. [pmid: 7872717].
Jahanzeb M, Mortimer JE, Yunus F, et al. Phase II trial of weekly vinorelbine and trastuzumab as first-line therapy in patients with HER2(+) metastatic breast cancer. Oncologist. 2002;7(5):410-7. Notes: Q2? Q3A? PII N25 BC TRZ CHT IHC FIS (on 25 of 39 tested by IHC); no information on kits/reagents etc. for IHC or FISH. [pmid: 12401903].
Janku F, Pribylova O, Zimovjanova M, et al. 4-years results of weekly trastuzumab and paclitaxel in the treatment of women with HER2/neu overexpressing advanced breast cancer: single institution prospective study. Bull Cancer. 2004;91(10):E279-83. Notes: Q2? PRO? FEW BC TRZ CHT IHC. [pmid: 15582895].
Jarvinen TA, Holli K, Kuukasjarvi T, Isola JJ. Predictive value of topoisomerase IIalpha and other prognostic factors for epirubicin chemotherapy in advanced breast cancer. Br J Cancer. 1998;77(12):2267-73. Notes: Q3A? PRO? N50 BC CHT HM?. [pmid: 9649144].
Jarvinen TA, Tanner M, Rantanen V, et al. Amplification and deletion of topoisomerase IIalpha associate with ErbB-2 amplification and affect sensitivity to topoisomerase II inhibitor doxorubicin in breast cancer. Am J Pathol. 2000;156(3):839-47. Notes: Q3A? RET N50 BC CHT? SBL. [pmid: 10702400]. [pmcid: 1876829].
Jarvinen TAH, Liu ET. Simultaneous amplification of HER-2 (ERBB2) and topoisomerase II(alpha) (TOP2A) genes - Molecular basis for combination chemotherapy in cancer. Curr Cancer Drug Targets. 2006;6(7):579-602. Notes: Q3A? NRA?. [pmid: 17100565].
Jensen BV, Johansen JS, Price PA. High levels of serum HER-2/neu and YKL-40 independently reflect aggressiveness of metastatic breast cancer. Clin Cancer Res. 2003;9(12):4423-34. Notes: Q4? PRO? N100 BC CHT ELS. [pmid: 14555515].
Jin O, Yan Y, Shen M, Cheng R. [The relationship between C-erbB-2 expression with cell proliferative activity and prognosis of nasopharyngeal carcinomas]. Hunan Yi Ke Da Xue Xue Bao. 1998;23(3):235-8. Notes: Q5 CS N? HNC HM?. [pmid: 10681746].
Jukkola A, Bloigu R, Soini Y, Savolainen ER, Holli K, Blanco G. c-erbB-2 positivity is a factor for poor prognosis in breast cancer and poor response to hormonal or chemotherapy treatment in advanced disease. Eur J Cancer. 2001;37(3):347-54. Notes: Q3A? Q3B? RET N100 BC CHT? HT? PCR IHC SBL. [pmid: 11239756].
Kandl H, Seymour L, Bezwoda WR. Soluble c-erbB-2 fragment in serum correlates with disease stage and predicts for shortened survival in patients with early-stage and advanced breast cancer. Br J Cancer. 1994;70(4):739-42. Notes: Q4? PRO? N50 BC T? ELS IHC?. [pmid: 7522511].
Kanematsu T, Yano S, Uehara H, Bando Y, Sone S. Phosphorylation, but not overexpression, of epidermal growth factor receptor is associated with poor prognosis of non-small cell lung cancer patients. Oncol Res. 2003;13(5):289-98. Notes: Q5 CS N25 LC IHC. [pmid: 12688680].
Kariya S, Ogawa Y, Nishioka A, et al. Relationship between hormonal receptors, HER-2, p53 protein, Bcl-2, and MIB-1 status and the antitumor effects of neoadjuvant anthracycline-based chemotherapy in invasive breast cancer patients. Radiat Med Med Imaging Radiat Oncol. 2005;23(3):189-94. Notes: Q3B? PRO? N25 BC CHT IHC?.
Kasimir-Bauer S, Mayer S, Bojko P, Borquez D, Neumann R, Seeber S. Survival of tumor cells in stem cell preparations and bone marrow of patients with high-risk or metastatic breast cancer after receiving dose-intensive or high-dose chemotherapy. Clin Cancer Res. 2001;7(6):1582-9. Notes: Q4? PRO? N25 BC CHT ELS. [pmid: 11410494].
Kasimir-Bauer S, Oberhoff C, Schindler AE, Seeber S. A summary of two clinical studies on tumor cell dissemination in primary and metastatic breast cancer: methods, prognostic significance and implication for alternative treatment protocols (Review). Int J Oncol. 2002;20(5):1027-34. Notes: Q4? PRO? N100 BC CHT? ELS. [pmid: 11956600].
Kasimir-Bauer S, Oberhoff C, Sliwinska K, Neumann R, Schindler AE, Seeber S. Evaluation of different methods for the detection of minimal residual disease in blood and bone marrow of patients with primary breast cancer: importance for clinical use?. Breast Cancer Res Treat. 2001;69(2):123-32. Notes: Q4? PRO? N100 BC T? ELS. [pmid: 11759818].
Kath R, Hoffken K, Otte C, et al. The neu-oncogene product in serum and tissue of patients with breast carcinoma. Ann Oncol. 1993;4(7):585-90. Notes: Q4 PRO? N100 BC T? O? ELS IHC. [pmid: 8103351].
Kato H, Arakawa A, Suzumori K, Kataoka N, Young SR. FISH analysis of BRCA1 copy number in paraffin-embedded ovarian cancer tissue samples. Exp Mol Pathol. 2004;76(2):138-42. Notes: Q5 CS N25 OC FIS. [pmid: 15010292].
Kaufmann M, Minckwitz VG, Finn HP, Schmid H, Goerttler K, Bastert G. Combination of grading and new biological factors (S-phase fraction and epidermal growth factor receptor) can predict relapse and survival in patients with node-negative primary breast cancer. Onkologie. 1994;17(2):166-72. Notes: Q5 CS N100 BC.
Kern JA, Slebos RJ, Top B, et al. C-erbB-2 expression and codon 12 K-ras mutations both predict shortened survival for patients with pulmonary adenocarcinomas. J Clin Invest. 1994;93(2):516-20. Notes: Q5 CS N25 LC HM?. [pmid: 7906694]. [pmcid: 293872].
Khan AJ, DiGiovanna MP, Ross DA, et al. Adenoid cystic carcinoma: a retrospective clinical review. Int J Cancer. 2001;96(3):149-58. Notes: Q5 CS N50 HNC HM?. [pmid: 11410883].
Killeen JL, Ortega-Lopez A, Shaha J, Shaha SH, Fu JB. Pathology of borderline HER-2/neu breast carcinoma: a biologically distinct phenotype. Breast Cancer Res Treat. 2006;98(1):99-108. Notes: Q1? Q2? RET N100 BC T? O? IHC FIS. [pmid: 16538540].
Kim R, Osaki A, Toge T. Pharmacokinetic and biochemical analysis in the treatment of weekly paclitaxel in relapsed breast cancer. Oncol Rep. 2001;8(5):1171-6. Notes: Q4? PRO N25 BC CHT ELS. [pmid: 11496337].
Kim YC, Park KO, Kern JA, et al. The interactive effect of Ras, HER2, P53 and Bcl-2 expression in predicting the survival of non-small cell lung cancer patients. Lung Cancer. 1998;22(3):181-90. Notes: Q5 CS N100 LC IHC. [pmid: 10048471].
Kim YS, Konoplev SN, Montemurro F, et al. HER-2/neu overexpression as a poor prognostic factor for patients with metastatic breast cancer undergoing high-dose chemotherapy with autologous stem cell transplantation. Clin Cancer Res. 2001;7(12):4008-12. Notes: Q3A? RET N50 BC CHT (HDC) IHC. [pmid: 11751494].
Kimura M, Sano M, Tabei T, et al. [Study of three-weekly docetaxel and weekly trastuzumab treatment in HER 2-overexpressing metastatic breast cancer patients]. Gan To Kagaku Ryoho. 2005;32(3):335-9. Notes: Q2? Q3A? PRO? N25 BC TRZ CHT IHC FIS. [pmid: 15791816].
Konecny G, Fritz M, Untch M, et al. HER-2/neu overexpression and in vitro chemosensitivity to CMF and FEC in primary breast cancer. Breast Cancer Res Treat. 2001;69(1):53-63. Notes: Q3A? (for intro/bkgd or discussion?) INV NRO. [pmid: 11759828].
Konecny G, Pauletti G, Pegram M, et al. Quantitative association between HER-2/neu and steroid hormone receptors in hormone receptor-positive primary breast cancer. J Natl Cancer Inst. 2003;95(2):142-53. Notes: Q3B? NRO?. [pmid: 12529347].
Konecny G, Slamon DJ. HER2 testing and correlation with efficacy of trastuzumab therapy. Oncology (Williston Park). 2002;16(11):1576-1578. Notes: Q2?. [pmid: 12469932].
Konecny GE, Thomssen C, Luck HJ, et al. HER-2/neu gene amplification and response to paclitaxel in patients with metastatic breast cancer. Women's Oncol Rev. 2004;4(4):277-8. Notes: Q3A?.
Kong SY, Kang JH, Kwon Y, et al. Serum HER-2 concentration in patients with primary breast cancer. J Clin Pathol. 2006;59(4):373-6. Notes: Q1? Q4? DAC? PRO? N50 BC T? O? IHC FIS ELS. [pmid: 16461567].
Kong SY, Nam BH, Lee KS, et al. Predicting tissue HER2 status using serum HER2 levels in patients with metastatic breast cancer. Clin Chem. 2006;52(8):1510-5. Notes: Q1? Q4? DAC? N100 BC T? O? IHC FIS ELS. [pmid: 16777917].
Kostler WJ, Brodowicz T, Hudelist G, et al. The efficacy of trastuzumab in Her-2/neu-overexpressing metastatic breast cancer is independent of p53 status. J Cancer Res Clin Oncol. 2005;131(7):420-8. Notes: Q2? PRO N100 BC TRZ HM?. [pmid: 15864644].
Kostler WJ, Hudelist G, Rabitsch W, et al. Insulin-like growth factor-1 receptor (IGF-1R) expression does not predict for resistance to trastuzumab-based treatment in patients with Her-2/neu overexpressing metastatic breast cancer. J Cancer Res Clin Oncol. 2006;132(1):9-18. Notes: Q2? PRO? N50 BC TRZ HM?. [pmid: 16184380].
Kostler WJ, Schwab B, Singer CF, et al. Monitoring of serum Her-2/neu predicts response and progression-free survival to trastuzumab-based treatment in patients with metastatic breast cancer. Clin Cancer Res. 2004;10(5):1618-24. Notes: Q4 PRO N50 BC TRZ ELS. [pmid: 15014012].
267 Kostler WJ, Steger GG, Soleiman A, et al. Monitoring of serum Her-2/neu predicts histopathological response to neoadjuvant trastuzumab-based therapy for breast cancer. Anticancer Res. 2004;24(2C):1127-30. Notes: Q4 PRO FEW BC TRZ ELS. [pmid: 15154635].
Kostopoulos I, Arapantoni-Dadioti P, Gogas H, et al. Evaluation of the prognostic value of HER-2 and VEGF in breast cancer patients participating in a randomized study with dose-dense sequential adjuvant chemotherapy. Breast Cancer Res Treat. 2006;96(3):251-61. Notes: Q3A? RCT N100 BC CHT IHC FIS. [pmid: 16538542].
Kostyleva OI, Gershtein ES, Dykhno AIu, Polotskii BE, Vasil'ev AV, Kushlinskii NE. [Clinical and prognostic importance of the expression of epidermal growth factor receptors in non-small-cell lung carcinoma]. Biull Eksp Biol Med. 1999;127(4):446-9. Notes: Q5? RCT? LC. [pmid: 10367133].
Krainer M, Brodowicz T, Zeillinger R, et al. Tissue expression and serum levels of HER-2/neu in patients with breast cancer. Oncology. 1997;54(6):475-81. Notes: Q4? PRO? N50 BC T? O? ELS. [pmid: 9394844].
Krecicki T, Jelen M, Zalesska-Krecicka M. C-erbB-2 immunostaining in laryngeal cancer. Acta Otolaryngol. 1999;119(3):392-5. Notes: Q5 CS N100 HNC IHC. [pmid: 10380748].
Kremser R, Obrist P, Spizzo G, et al. Her2/neu overexpression in differentiated thyroid carcinomas predicts metastatic disease. Virchows Arch. 2003;442(4):322-8. Notes: Q5 CS N100 HNC IHC. [pmid: 12715168].
Kreutzkamp B. Cetuximab in addition to radiotherapy improves the result of treament of locoregional advanced head and neck tumors: CETUXIMAB ZUSATZLICH ZUR RADIOTHERAPIE VERBESSERT ERGEBNIS. Krankenhauspharmazie. 2006;27(12):547-8. Notes: Q5? D? HNC.
Kroger N, Milde-Langosch K, Riethdorf S, et al. Prognostic and predictive effects of immunohistochemical factors in high-risk primary breast cancer patients. Clin Cancer Res. 2006;12(1):159-68. Notes: Q3A? RCT N100 BC CHT (HDC) HM?. [pmid: 16397038].
Kronblad A, Jirstrom K, Ryden L, Nordenskjold B, Landberg G. Hypoxia inducible factor-1alpha is a prognostic marker in premenopausal patients with intermediate to highly differentiated breast cancer but not a predictive marker for tamoxifen response. Int J Cancer. 2006;118(10):2609-16. Notes: Q3B? RCT N100 BC HT HM?. [pmid: 16381002].
Kuhn EJ, Kurnot RA, Sesterhenn IA, Chang EH, Moul JW. Expression of the c-erbB-2 (HER-2/neu) oncoprotein in human prostatic carcinoma. J Urol. 1993;150(5 Pt 1):1427-33. Notes: Q5 CS N50 PC IHC. [pmid: 8105108].
Kummel S, Eggemann H, Luftner D, et al. Changes in the circulating plasma levels of VEGF and VEGF-D after adjuvant chemotherapy in patients with breast cancer and 1 to 3 positive lymph nodes. Anticancer Res. 2006;26(2 C):1719-26. Notes: Q3A? RCT N100 BC CHT (HDC) IHC. [pmid: 16617567].
Kupryjanczyk J, Madry R, Plisiecka-Halasa J, et al. TP53 status determines clinical significance of ERBB2 expression in ovarian cancer. Br J Cancer. 2004;91(11):1916-23. Notes: Q5 CS N100 OC IHC. [pmid: 15545967].
Kynast B, Binder L, Marx D, et al. Determination of a fragment of the c-erbB-2 translational product p185 in serum of breast cancer patients. J Cancer Res Clin Oncol. 1993;119(5):249-52. Notes: Q4? PRO? N50 BC T? O? ELS. [pmid: 8095050].
Lal P, Tan LK, Chen B. Correlation of HER-2 status with estrogen and progesterone receptors and histologic features in 3,655 invasive breast carcinomas. Am J Clin Pathol. 2005;123(4):541-6. Notes: Q1? Q3B? DAC RET N100 T? O? IHC FIS. [pmid: 15743737].
Langer R, Specht K, Becker K, et al. Association of pretherapeutic expression of chemotherapy-related genes with response to neoadjuvant chemotherapy in Barrett carcinoma. Clin Cancer Res. 2005;11(20):7462-9. Notes: Q5 CS N25 HNC RNA. [pmid: 16243820].
Lassus H, Leminen A, Vayrynen A, et al. ERBB2 amplification is superior to protein expression status in predicting patient outcome in serous ovarian carcinoma. Gynecol Oncol. 2004;92(1):31-9. Notes: Q5 CS N? OC CIS IHC. [pmid: 14751135].
Lassus H, Sihto H, Leminen A, et al. Gene amplification, mutation, and protein expression of EGFR and mutations of ERBB2 in serous ovarian carcinoma. J Mol Med. 2006;84(8):671-81. Notes: Q5 CS N100 OC CIS. [pmid: 16607561].
Lee D. Phase II data with ZD6474, a small-molecule kinase inhibitor of epidermal growth factor receptor and vascular endothelial growth factor receptor, in previously treated advanced non-small-cell lung cancer. Clin Lung Cancer. 2005;7(2):89-91. Notes: Q5? PII LC. [pmid: 16179094].
Leeson SC, Morphopoulos G, Buckley CH, Hale RJ. c-erbB-2 oncogene expression in Stage I epithelial ovarian cancer. Br J Obstet Gynaecol. 1995;102(1):65-7. Notes: Q5? D? OC. [pmid: 7833316].
Leitzel K, Teramoto Y, Konrad K, et al. Elevated serum c-erbB-2 antigen levels and decreased response to hormone therapy of breast cancer. J Clin Oncol. 1995;13(5):1129-35. Notes: Q4? RCT N100 BC HT ELS. [pmid: 7738618].
Leitzel K, Teramoto Y, Sampson E, et al. Elevated soluble c-erbB-2 antigen levels in the serum and effusions of a proportion of breast cancer patients. J Clin Oncol. 1992;10(9):1436-43. Notes: Q4? PRO? N100 BC T? O? ELS. [pmid: 1355522].
Leng J, Lang J, Shen K, Guo L. Overexpression of p53, EGFR, c-erbB2 and c-erbB3 in endometrioid carcinoma of the ovary. Chin Med Sci J. 1997;12(2):67-70. Notes: Q5 CS N25 OC IHC. [pmid: 11324501].
Leonard DS, Hill AD, Kelly L, Dijkstra B, McDermott E, O'Higgins NJ. Anti-human epidermal growth factor receptor 2 monoclonal antibody therapy for breast cancer. Br J Surg. 2002;89(3):262-71. Notes: Q2? SR (but no Methods section) N? BC TRZ HM?. [pmid: 11872048].
Lewis JE, Olsen KD, Sebo TJ. Carcinoma ex pleomorphic adenoma: pathologic analysis of 73 cases. Hum Pathol. 2001;32(6):596-604. Notes: Q5 CS N50 HNC IHC. [pmid: 11431714].
Leyland-Jones B, Gelmon K, Ayoub JP, et al. Pharmacokinetics, safety, and efficacy of trastuzumab administered every three weeks in combination with paclitaxel. J Clin Oncol. 2003;21(21):3965-71. Notes: Q2? PRO N25 BC TRZ + CHT IHC (+FIS for some). [pmid: 14507946].
Li L, Zhong YP, Zhang W, Zhang JQ, Yao ZQ. [Relationship of expression of C-erbB2, C-erbB3, and C-erbB4 with ovarian carcinoma]. Ai Zheng. 2004;23(5):568-72. Notes: Q5 CS N25 PC IHC. [pmid: 15142456].
Linke SP, Bremer TM, Herold CD, Sauter G, Diamond C. A multimarker model to predict outcome in tamoxifen-treated breast cancer patients. Clin Cancer Res. 2006;12(4):1175-83. Notes: Q3B? RET N100 BC HT HM? TMA?. [pmid: 16489071].
Lipton A, Ali SM, Leitzel K, et al. Elevated serum Her-2/neu level predicts decreased response to hormone therapy in metastatic breast cancer. J Clin Oncol. 2002;20(6):1467-72. Notes: Q4? RCT N100 BC HT ELS. [pmid: 11896093].
Lipton A, Leitzel K, Ali SM, et al. Serum HER-2/neu conversion to positive at the time of disease progression in patients with breast carcinoma on hormone therapy. Cancer. 2005;104(2):257-63. Notes: Q4? PRO? N100 BC HT ELS. [pmid: 15952182].
Liu CJ, Lin SC, Chen YJ, Chang KM, Chang KW. Array-comparative genomic hybridization to detect genomewide changes in microdissected primary and metastatic oral squamous cell carcinomas. Mol Carcinog. 2006;45(10):721-31. Notes: Q5 CS N25 HNC IHC. [pmid: 16676365].
Liu L, Yang K. [A study on C-erbB2, nm23 and p53 expressions in epithelial ovarian cancer and their clinical significance]. Zhonghua Fu Chan Ke Za Zhi. 1999;34(2):101-4. Notes: Q5 CS N? OC HM?. [pmid: 11263193].
Lopes MA, da Cruz Perez DE, de Abreu Alves F, de Almeida OP, Kowalski LP. Clinicopathologic and immunohistochemical study of intraoral mucoepidermoid carcinoma. Otolaryngol Head Neck Surg. 2006;134(4):622-6. Notes: Q5? CS HNC IT?. [pmid: 16564385].
Love RR, Duc NB, Havighurst TC, et al. Her-2/neu overexpression and response to oophorectomy plus tamoxifen adjuvant therapy in estrogen receptor-positive premenopausal women with operable breast cancer. J Clin Oncol. 2003;21(3):453-7. Notes: Q3B? RCT N100 BC HT IHC. [pmid: 12560434].
Ludovini V, Sidoni A, Pistola L, et al. Evaluation of the prognostic role of vascular endothelial growth factor and microvessel density in stages I and II breast cancer patients. Breast Cancer Res Treat. 2003;81(2):159-68. Notes: Q3A? RCT N100 BC CHT HM?. [pmid: 14572158].
Luftner D, Cheli C, Mickelson K, Sampson E, Possinger K. ADVIA Centaur HER-2/neu shows value in monitoring patients with metastatic breast cancer. Int J Biol Markers. 2004;19(3):175-82. Notes: Q4? PRO N50 BC T? ELS. [pmid: 15503818].
Luftner D, Henschke P, Kafka A, et al. Discordant results obtained for different methods of HER-2/neu testing in breast cancer—a question of standardization, automation and timing. Int J Biol Markers. 2004;19(1):1-13. Notes: Q1? Q4? DAC? N25 BC T? O? IHC FIS ELS. [pmid: 15077921].
Luftner D, Jung A, Schmid P, et al. Upregulation of HER-2/neu by ovarian ablation: results of a randomized trial comparing leuprorelin to CMF as adjuvant therapy in node-positive breast cancer patients. Breast Cancer Res Treat. 2003;80(3):245-55. Notes: Q4? RCT N100 BC HT ELS CORPORATE NAME: Takeda Adjuvant Breast Cancer Study with Leuprorelin Study Group. [pmid: 14503797].
Luftner D, Schnabel S, Possinger K. c-erbB-2 in serum of patients receiving fractionated paclitaxel chemotherapy. Int J Biol Markers. 1999;14(2):55-9. Notes: Q4 PRO N25 BC CHT ELS. [pmid: 10399623].
Lumachi F, Basso SM. Serum tumor markers in patients with breast cancer. Expert Rev Anticancer Ther. 2004;4(5):921-31. Notes: Q4? NRA?. [pmid: 15485325].
Ma BB, Poon TC, To KF, et al. Prognostic significance of tumor angiogenesis, Ki 67, p53 oncoprotein, epidermal growth factor receptor and HER2 receptor protein expression in undifferentiated nasopharyngeal carcinoma—a prospective study. Head Neck. 2003;25(10):864-72. Notes: Q5 CS N50 HNC IHC. [pmid: 12966511].
MacGrogan G, Mauriac L, Durand M, et al. Primary chemotherapy in breast invasive carcinoma: predictive value of the immunohistochemical detection of hormonal receptors, p53, c-erbB-2, MiB1, pS2 and GST pi. Br J Cancer. 1996;74(9):1458-65. Notes: Q3A? RET PRG N100 BC CHT IHC. [pmid: 8912545].
Manna Edel F, Teixeira LC, Alvarenga M. Association between immunohistochemical expression of topoisomerase IIalpha, HER2 and hormone receptors and response to primary chemotherapy in breast cancer. Tumori. 2006;92(3):222-9. Notes: Q3A? RET N100 BC CHT IHC (no reflex FISH & IHC 2+ considered HER2-). [pmid: 16869240].
Mansour OA, Zekri AR, Harvey J, Teramoto Y, el-Ahmady O. Tissue and serum c-erbB-2 and tissue EGFR in breast carcinoma: three years follow-up. Anticancer Res. 1997;17(4B):3101-6. Notes: Q4? PRO? N100 BC T? ELS. [pmid: 9329611].
Marcom PK, Isaacs C, Harris L et al. The combination of letrozole and trastuzumab as first or second-line biological therapy produces durable responses in a subset of HER2 positive and ER positive advanced breast cancers. Breast Cancer Res Treat 2006. Notes: Q2 (n=6 IHC 2+ FISH-; response data only) Q3B? PRO N25 BC TRZ HT IHC FIS
Mark HF, Feldman D, Das S, et al. Fluorescence in situ hybridization study of HER-2/neu oncogene amplification in prostate cancer. Exp Mol Pathol. 1999;66(2):170-8. Notes: Q5 CS N50 PC NRO FIS. [pmid: 10409446].
Martin-Richard M, Munoz M, Albanell J, et al. Serial topoisomerase II expression in primary breast cancer and response to neoadjuvant anthracycline-based chemotherapy. Oncology. 2004;66(5):388-94. Notes: Q3A? PRO? N25 BC CHT IHC. [pmid: 15331926].
Mass RD, Press MF, Anderson S, et al. Evaluation of clinical outcomes according to HER2 detection by fluorescence in situ hybridization in women with metastatic breast cancer treated with trastuzumab. Clin Breast Cancer. 2005;6(3):240-6. Notes: Q2A? RET N100 BC TRZ IHC FIS. [pmid: 16137435].
Mayr D, Kanitz V, Amann G, et al. HER-2/neu gene amplification in ovarian tumours: A comprehensive immunohistochemical and FISH analysis on tissue microarrays. Histopathology. 2006;48(2):149-56. Notes: Q5 CS N100 OC IHC FIS. [pmid: 16405663].
Mazouni C, Hall A, Broglio K, et al. Kinetics of serum HER-2/neu changes in patients with HER-2-positive primary breast cancer after initiation of primary chemotherapy. Cancer. 2007;109(3):496-501. Notes: Q4? RCT N25 BC TRZ CHT ELS. [pmid: 17149760].
Meenakshi A, Kumar RS, Kumar NS. ELISA for quantitation of serum C-erbB-2 oncoprotein in breast cancer patients. J Immunoassay Immunochem. 2002;23(3):293-305. Notes: Q4? ADS? N100 BC T? O? ELS. [pmid: 12227416].
Mehdi SA, Tatum AH, Newman NB, et al. Prognostic markers in resected stage I and II non small-cell lung cancer: an analysis of 260 patients with 5 year follow-up. Clin Lung Cancer. 1999;1(1):59-67. discussion 68–9. Notes: Q5 CS N100 LC IHC. [pmid: 14725752].
Mehta RR, McDermott JH, Hieken TJ, et al. Plasma c-erbB-2 levels in breast cancer patients: prognostic significance in predicting response to chemotherapy. J Clin Oncol. 1998;16(7):2409-16. Notes: Q4? PRO? N50 BC CHT ELS. [pmid: 9667258].
Menard S, Valagussa P, Pilotti S, et al. Response to cyclophosphamide, methotrexate, and fluorouracil in lymph node-positive breast cancer according to HER2 overexpression and other tumor biologic variables. J Clin Oncol. 2001;19(2):329-35. Notes: Q3A? RCT N100 BC CHT IHC. [pmid: 11208823].
Mieog JS, van der Hage JA, van de Vijuer MJ, van de Velde CJ. Tumour response to preoperative anthracycline-based chemotherapy in operable breast cancer: the predictive role of p53 expression. Eur J Cancer. 2006;42(10):1369-79. Notes: Q3A? RET N100 BC CHT (neoadj) HM? CORPORATE NAME: Cooperating Investigators of the EORTC. [pmid: 16766179].
Miles DW, Harris WH, Gillett CE, Smith P, Barnes DM. Effect of c-erbB2 and estrogen receptor status on survival of women with primary breast cancer treated with adjuvant cyclophosphamide/methotrexate/fluorouracil. Int J Cancer. 1999;84(4):354-9. Notes: Q3A? RCT N100 BC CHT HM?. [pmid: 10404085].
Mimura K, Kono K, Hanawa M, et al. Frequencies of HER-2/neu expression and gene amplification in patients with oesophageal squamous cell carcinoma. Br J Cancer. 2005;92(7):1253-60. Notes: Q5 CS N50 HNC FIS IHC. [pmid: 15785739].
Minisini AM, Di Loreto C, Mansutti M, et al. Topoisomerase IIalpha and APE/ref-1 are associated with pathologic response to primary anthracycline-based chemotherapy for breast cancer. Cancer Lett. 2005;224(1):133-9. Notes: Q3A? RET N50 BC CHT IHC. [pmid: 15911109].
Minna JD, Gazdar AF, Sprang SR, Herz J. Cancer. A bull's eye for targeted lung cancer therapy. Science. 2004;304(5676):1458-61. Notes: Q5? D? LC. [pmid: 15178790].
Mitsudomi T, Takahashi T. [Genetic alteration of lung cancer as a prognostic marker and its therapeutic implications]. Gan To Kagaku Ryoho. 1997;24(Suppl 3):345-52. Notes: Q5 CS N100 LC. [pmid: 9369906].
Mitze M, Kreienberg R, Weikel W, Beck T. Demonstration of the c-erbB-2 oncoprotein in the serum of patients with breast cancer: NACHWEIS DES C-ERBB-2 ONKOPROTEINS IM SERUM VON PATIENTINNEN MIT MAMMAKARZINOMEN. ARCH GYNECOL OBSTET. 1993;254(14):838-40. Notes: Q4?.
Miyazono F, Metzger R, Warnecke-Eberz U, et al. Quantitative c-erbB-2 but not c-erbB-1 mRNA expression is a promising marker to predict minor histopathologic response to neoadjuvant radiochemotherapy in oesophageal cancer. Br J Cancer. 2004;91(4):666-72. Notes: Q5 CS N? HNC. [pmid: 15213712].
Modjtahedi H. Molecular therapy of head and neck cancer. Cancer Metastasis Rev. 2005;24(1):129-46. Notes: Q5 NRA NPD HNC. [pmid: 15785877].
Mohsin SK, Weiss HL, Gutierrez MC, et al. Neoadjuvant trastuzumab induces apoptosis in primary breast cancers. J Clin Oncol. 2005;23(11):2460-8. Notes: Q2? Q3A? PRO N25 BC TRZ CHT HM?. [pmid: 15710948].
Molina R, Filella X, Zanon G, et al. Prospective evaluation of tumor markers (c-erbB-2 oncoprotein, CEA and CA 15.3) in patients with locoregional breast cancer. Anticancer Res. 2003;23(2A):1043-50. Notes: Q4? RET PRG N100 BC T? ELS?. [pmid: 12820345].
Molina R, Jo J, Filella X, et al. C-erbB-2, CEA and CA 15.3 serum levels in the early diagnosis of recurrence of breast cancer patients. Anticancer Res. 1999;19(4A):2551-5. Notes: Q4 PRO N100 BC T? ELS?. [pmid: 10470193].
Molina R, Jo J, Filella X, et al. c-erbB-2 oncoprotein, CEA, and CA 15.3 in patients with breast cancer: prognostic value. Breast Cancer Res Treat. 1998;51(2):109-19. Notes: Q4? RET PRG N100 BC T? ELS?. [pmid: 9879773].
Molina R, Jo J, Filella X, et al. C-erbB-2 oncoprotein in the sera and tissue of patients with breast cancer. Utility in prognosis. Anticancer Res. 1996;16(4B):2295-300. Notes: Q4? RET PRG N100 BC T? ELS?. [pmid: 8694559].
Molina R, Jo J, Zanon G, et al. Utility of C-erbB-2 in tissue and in serum in the early diagnosis of recurrence in breast cancer patients: comparison with carcinoembryonic antigen and CA 15.3. Br J Cancer. 1996;74(7):1126-31. Notes: Q4? PRO PRG N100 BC T? ELS?. [pmid: 8855986].
Montemurro F, Choa G, Faggiuolo R, et al. Safety and activity of docetaxel and trastuzumab in HER2 overexpressing metastatic breast cancer: a pilot phase II study. Am J Clin Oncol. 2003;26(1):95-7. Notes: Q2? Q3A? PII N25 BC TRZ CHT IHC only. [pmid: 12576933].
Morabito A, Longo R, Gattuso D, et al. Trastuzumab in combination with gemcitabine and vinorelbine as second-line therapy for HER-2/neu overexpressing metastatic breast cancer. Oncol Rep. 2006;16(2):393-8. Notes: Q2? Q3A? PRO? N25 BC TRZ CHT IHC. [pmid: 16820921].
Morena AM, Oshima CT, Gebrim LH, et al. Early nuclear alterations and immunohistochemical expression of Ki-67, Erb-B2, vascular endothelial growth factor (VEGF), transforming growth factor (TGF-beta1) and integrine-linked kinase (ILK) two days after tamoxifen in breast carcinoma. Neoplasma. 2004;51(6):481-6. Notes: Q3B? PRO FEW BC HT IHC. [pmid: 15640959].
Mori S, Mori Y, Mukaiyama T, et al. In vitro and in vivo release of soluble erbB-2 protein from human carcinoma cells. Jpn J Cancer Res. 1990;81(5):489-94. Notes: Q4? D? FEW BC T? WBL?. [pmid: 1974247].
Morrison LE, Jewell SS, Usha L, et al. Effects of ERBB2 amplicon size and genomic alterations of chromosomes 1, 3, and 10 on patient response to trastuzumab in metastatic breast cancer. Genes Chromosomes Cancer. 2007;46(4):397-405. Notes: Q2? RET CS N25 BC TRZ FIS. [pmid: 17243161].
Mottolese M, Benevolo M, Del Monte G, et al. Role of P53 and BCL-2 in high-risk breast cancer patients treated with adjuvant anthracycline-based chemotherapy. J Cancer Res Clin Oncol. 2000;126(12):722-9. Notes: Q3A? RET PRG N100 BC CHT IHC. [pmid: 11153146].
Mottolese M, Orlandi G, Sperduti I, et al. Bio-pathologic characteristics related to chromosome 11 aneusomy and cyclin D1 gene status in surgically resected stage I and II breast cancer: Identification of an adverse prognostic profile. Am J Surg Pathol. 2007;31(2):247-54. Notes: Q3A? RET? N100 BC CHT IHC. [pmid: 17255770].
Moulder SL, Arteaga CL. A phase I/II trial of trastuzumab and gefitinib in patients with metastatic breast cancer that overexpresses HER2/neu (ErbB-2). Clin Breast Cancer. 2003;4(2):142-5. Notes: Q2? Q3A?. [pmid: 12864943].
Mueller RE, Parkes RK, Andrulis I, O'Malley FP. Amplification of the TOP2A gene does not predict high levels of topoisomerase II alpha protein in human breast tumor samples. Genes Chromosomes Cancer. 2004;39(4):288-97. Notes: Q1? Q3A? D? N50 BC T? IHC FIS. [pmid: 14978790].
Muller S, Vigneswaran N, Gansler T, Gramlich T, DeRose PB, Cohen C. c-erbB-2 oncoprotein expression and amplification in pleomorphic adenoma and carcinoma ex pleomorphic adenoma: relationship to prognosis. Mod Pathol. 1994;7(6):628-32. Notes: Q5 CS N25 HNC. [pmid: 7991521].
Muller-Tidow C, Diederichs S, Bulk E, et al. Identification of metastasis-associated receptor tyrosine kinases in non-small cell lung cancer. Cancer Res. 2005;65(5):1778-82. Notes: Q5 CS N50 LC HM?. [pmid: 15753374].
Muller V, Witzel I, Pantel K, et al. Prognostic and predictive impact of soluble epidermal growth factor receptor (sEGFR) protein in the serum of patients treated with chemotherapy for metastatic breast cancer. Anticancer Res. 2006;26(2B):1479-87. Notes: Q4? D? N100 BC CHT ELS. [pmid: 16619561].
Muss HB, Thor AD, Berry DA, et al. c-erbB-2 expression and response to adjuvant therapy in women with node-positive early breast cancer. NEW ENGL J MED. 1994;330(18):1260-6. Notes: Q5 RCT N100 BC. [pmid: 7908410].
Nabholtz JM, Reese DM, Lindsay MA, Riva A. HER2-positive breast cancer: update on Breast Cancer International Research Group trials. Clin Breast Cancer. 2002;3(Suppl 2):S75-9. Notes: Q2? Q3A? RCT N100 BC TRZ CHT FIS. [pmid: 12435291].
Nagler RM, Kerner H, Laufer D, Ben-Eliezer S, Minkov I, Ben-Itzhak O. Squamous cell carcinoma of the tongue: the prevalence and prognostic roles of p53, Bcl-2, c-erbB-2 and apoptotic rate as related to clinical and pathological characteristics in a retrospective study. Cancer Lett. 2002;186(2):137-50. Notes: Q5 CS N100 HNC IHC. [pmid: 12213283].
Nakamura H, Kawasaki N, Taguchi M, Kabasawa K. Association of HER-2 overexpression with prognosis in nonsmall cell lung carcinoma: a metaanalysis. Cancer. 2005;103(9):1865-73. Notes: Q5 MA LC. [pmid: 15770690].
Nakamura H, Kawasaki N, Taguchi M, Kabasawa K. Survival impact of epidermal growth factor receptor overexpression in patients with non-small cell lung cancer: a meta-analysis. Thorax. 2006;61(2):140-5. Notes: NRQ MA HNM LC. [pmid: 16284218]. [pmcid: 2104592].
Nakamura T, Nekarda H, Hoelscher AH, et al. Prognostic value of DNA ploidy and c-erbB-2 oncoprotein overexpression in adenocarcinoma of Barrett's esophagus. Cancer. 1994;73(7):1785-94. Notes: Q5 CS N50 HNC IHC. [pmid: 7907940].
Narita T, Funahashi H, Satoh Y, Imai T, Takagi H. Quantitative analysis of c-erbB-2 protein in breast cancer tissue by enzyme immunoassay. Jpn J Clin Oncol. 1994;24(2):74-8. Notes: Q4? D? N50 BC T? ELS. [pmid: 7908994].
Narita T, Funahashi H, Satoh Y, Takagi H. [C-erb B-2 protein in the sera of breast cancer patients]. Gan To Kagaku Ryoho. 1992;19(6):909-11. Notes: Q4?. [pmid: 1351384].
Narita T, Funahashi H, Satoh Y, Takagi H. C-erbB-2 protein in the sera of breast cancer patients. Breast Cancer Res Treat. 1992;24(2):97-102. Notes: Q4? D? N100 BC T? ELS. [pmid: 8095169].
Nazar G, Gonzalez MV, Garcia JM, Llorente JL, Rodrigo JP, Suarez C. Amplification of CCND1, EMS1, PIK3CA, and ERBB oncogenes in ethmoid sinus adenocarcinomas. Otolaryngol Head Neck Surg. 2006;135(1):135-9. Notes: Q5 CS FEW HNC PCR. [pmid: 16815198].
Neckers L. Heat shock protein 90 inhibition by 17-allylamino-17- demethoxygeldanamycin: a novel therapeutic approach for treating hormone-refractory prostate cancer. Clin Cancer Res. 2002;8(5):962-6. Notes: Q5? D? PC. [pmid: 12006507].
Nemunaitis J, Klemow S, Tong A, et al. Prognostic value of K-ras mutations, ras oncoprotein, and c-erb B-2 oncoprotein expression in adenocarcinoma of the lung. Am J Clin Oncol. 1998;21(2):155-60. Notes: Q5 RET CS N100 LC. [pmid: 9537203].
Neskovic-Konstantinovic Z, Susnjar S, Nikolic-Vukosavljevic D, et al. Primarily tamoxifen-unresponsive, steroid receptor-positive breast cancer may respond to an aromatase inhibition: A pilot study. J BU ON. 2005;10(1):53-8. Notes: Q3B? RET FEW BC HT IHC.
Newby JC, Johnston SRD, Smith IE, Dowsett M. Expression of epidermal growth factor receptor and c-erbB2 during the development of tamoxifen resistance in human breast cancer. CLIN CANC RES. 1997;3(9):1643-51. Notes: Q3B RET N100 BC HT IHC.
Nguyen LH, Black MJ, Hier M, Chauvin P, Rochon L. HER2/neu and Ki-67 as prognostic indicators in mucoepidermoid carcinoma of salivary glands. J Otolaryngol. 2003;32(5):328-31. Notes: Q5 RET CS N25 HNC IHC. [pmid: 14974865].
Nicholson RI, McClelland RA, Finlay P, et al. Relationship between EGF-R, c-erbB-2 protein expression and Ki67 immunostaining in breast cancer and hormone sensitivity. Eur J Cancer. 1993;29A(7):1018-23. Notes: Q3B? RET N100 BC HT IHC. [pmid: 8098946].
Nicholson RI, McClelland RA, Gee JMW, et al. Epidermal growth factor receptor expression in breast cancer: Association with response to endocrine therapy. BREAST CANCER RES TREAT. 1994;29(1):117-25. Notes: Q3B? RET N100 BC HT IHC. [pmid: 7912565].
Nielsen JS, Jakobsen E, Holund B, Bertelsen K, Jakobsen A. Prognostic significance of p53, Her-2, and EGFR overexpression in borderline and epithelial ovarian cancer. Int J Gynecol Cancer. 2004;14(6):1086-96. Notes: Q5 CS N100 OC IHC. [pmid: 15571614].
Nieto Y, Cagnoni PJ, Nawaz S, et al. Evaluation of the predictive value of Her-2/neu overexpression and p53 mutations in high-risk primary breast cancer patients treated with high-dose chemotherapy and autologous stem-cell transplantation. J Clin Oncol. 2000;18(10):2070-80. Notes: Q3A? RET N100 BC CHT (HDC) IHC. [pmid: 10811672].
Nijman HW, Kenemans P, Poort-Keesom RJ, et al. Influence of chemotherapy on the expression of p53, HER-2/neu and proliferation markers in ovarian cancer. Eur J Obstet Gynecol Reprod Biol. 1999;83(2):201-6. Notes: Q5 CS FEW OC IHC. [pmid: 10391533].
Nijman HW, van Diest PJ, Poort-Keesom RJ, et al. T cell infiltration and MHC I and II expression in the presence of tumor antigens: An immunohistochemical study in patients with serous epithelial ovarian cancer. Eur J Obstet Gynecol Reprod Biol. 2001;94(1):114-20. Notes: Q5 CS N25 OC HM?. [pmid: 11134836].
Nio Y, Itakura M, Omori H, et al. Implication of HER-2/neu overexpression for the efficacy of oral fluoropyrimidine-based adjuvant chemotherapy in the patients with estrogen receptor negative breast cancer after surgery. Anticancer Res. 2003;23(1 B):745-53. Notes: Q3AB? RET N100 BC CHT HT IHC. [pmid: 12680178].
Nunes RA, Harris LN. The HER2 extracellular domain as a prognostic and predictive factor in breast cancer. Clin Breast Cancer. 2002;3(2):125-35. discussion 136–7. Notes: NRA Q4. [pmid: 12123536].
O'Byrne KJ, Cox G, Swinson D, et al. Towards a biological staging model for operable non-small cell lung cancer. Lung Cancer. 2001;34(Suppl 2):S83-9. Notes: Q5 CS N? LC HM?. [pmid: 11720747].
O-charoenrat P, Rhys-Evans PH, Archer DJ, Eccles SA. C-erbB receptors in squamous cell carcinomas of the head and neck: clinical significance and correlation with matrix metalloproteinases and vascular endothelial growth factors. Oral Oncol. 2002;38(1):73-80. Notes: Q5 CS N50 HNC HM?. [pmid: 11755824].
O'Shaughnessy JA, Vukelja S, Marsland T, Kimmel G, Ratnam S, Pippen JE. Phase II study of trastuzumab plus gemcitabine in chemotherapy-pretreated patients with metastatic breast cancer. Clin Breast Cancer. 2004;5(2):142-7. Notes: Q2? Q3? PII N50 BC TRZ CHT IHC. [pmid: 15245619].
Okegawa T, Kinjo M, Nutahara K, Higashihara E. Pretreatment serum level of HER2/nue as a prognostic factor in metastatic prostate cancer patients about to undergo endocrine therapy. Int J Urol. 2006;13(9):1197-201. Notes: Q5 CS N100 PC HM?. [pmid: 16984552].
Onn A, Choe DH, Herbst RS, et al. Tumor cavitation in stage I non-small cell lung cancer: epidermal growth factor receptor expression and prediction of poor outcome. Radiology. 2005;237(1):342-7. Notes: Q5 CS N50 LC HM?. [pmid: 16183941].
Onn A, Correa AM, Gilcrease M, et al. Synchronous overexpression of epidermal growth factor receptor and HER2-neu protein is a predictor of poor outcome in patients with stage I non-small cell lung cancer. Clin Cancer Res. 2004;10(1 Pt 1):136-43. Notes: Q5 CS N100 LC IHC. [pmid: 14734462].
Osaki A, Nomura Y. Relative effects of immunohistochemical expressions of c-erbB-2, p53, and bcl-2 oncoproteins on the survival of advanced breast cancer patients after endocrine therapy. INT J ONCOL. 1996;9(1):131-6. Notes: Q3B? PRO? N50 BC HT IHC.
Paik S, Bryant J, Park C, et al. erbB-2 and response to doxorubicin in patients with axillary lymph node-positive, hormone receptor-negative breast cancer. J Natl Cancer Inst. 1998;90(18):1361-70. Notes: Q3A RCT N100 BC CHT IHC. [pmid: 9747867].
Paik S, Bryant J, Tan-Chiu E, et al. HER2 and choice of adjuvant chemotherapy for invasive breast cancer: National Surgical Adjuvant Breast and Bowel Project Protocol B-15. J Natl Cancer Inst. 2000;92(24):1991-8. Notes: Q3A RCT N100 BC CHT IHC. [pmid: 11121461].
Pallud C, Guinebretiere JM, Guepratte S, et al. Tissue expression and serum levels of the oncoprotein HER-2/neu in 157 primary breast tumours. Anticancer Res. 2005;25(2B):1433-40. Notes: Q4? NRO? RET N100 BC T? IHC ELS. [pmid: 15865102].
Pan Q, Bao LW, Kleer CG, et al. Protein kinase C epsilon is a predictive biomarker of aggressive breast cancer and a validated target for RNA interference anticancer therapy. Cancer Res. 2005;65(18):8366-71. Notes: Q3AB CS N100 BC HM?. [pmid: 16166314].
Papaldo P, Fabi A, Ferretti G, et al. A phase II study on metastatic breast cancer patients treated with weekly vinorelbine with or without trastuzumab according to HER2 expression: changing the natural history of HER2-positive disease. Ann Oncol. 2006;17(4):630-6. Notes: Q2? Q3A? PII N50 BC TRZ CHT IHC w FIS if 2+. [pmid: 16410363].
Paradiso A, Mangia A, Chiriatti A, et al. Biomarkers predictive for clinical efficacy of taxol-based chemotherapy in advanced breast cancer. Ann Oncol. 2005;16(SUPPL. 4):iv14-iv19. Notes: Q3A D? N50 BC CHT IHC. [pmid: 15923415].
Parise Junior O, Carvalho LV, Miguel RE, Kowalski LP. Prognostic impact of p53, c-erbB-2 and epidermal growth factor receptor on head and neck carcinoma. Sao Paulo Med J. 2004;122(6):264-8. Notes: Q5 CS N50 HNC IHC. [pmid: 15692721].
Park K, Han S, Gwak GH, Kim HJ, Kim J, Kim KM. Topoisomerase II-alpha gene deletion is not frequent as its amplification in breast cancer. Breast Cancer Res Treat. 2006;98(3):337-42. Notes: Q3A? RET N100 BC CHT HM? TMA?. [pmid: 16502015].
Parton M, Dowsett M, Ashley S, Hills M, Lowe F, Smith IE. High incidence of HER-2 positivity in inflammatory breast cancer. Breast. 2004;13(2):97-103. Notes: Q1? Q3A? PRO N25 BC CHT IHC FIS. [pmid: 15019688].
Pectasides D, Gaglia A, Arapantoni-Dadioti P, et al. HER-2/neu status of primary breast cancer and corresponding metastatic sites in patients with advanced breast cancer treated with trastuzumab-based therapy. Anticancer Res. 2006;26(1B):647-53. Notes: Q1? Q2? Q4? D? FEW BC TRZ IHC CIS ELS. [pmid: 16739334].
Peethambaram PP, Cliby WA, Lubiniecki G, et al. Her-2/neu expression in ovarian cancer: pre- and postexposure to platinum chemotherapy. Gynecol Oncol. 2003;89(1):99-104. Notes: Q5 CS N25 OC IHC. [pmid: 12694661].
Pegram MD, Pienkowski T, Northfelt DW, et al. Results of two open-label, multicenter phase II studies of docetaxel, platinum salts, and trastuzumab in HER2-positive advanced breast cancer. J Natl Cancer Inst. 2004;96(10):759-69. Notes: Q1? Q2? Q3A? PII N50 BC TRZ CHT IHC FIS. [pmid: 15150304].
Pegram MD, Slamon DJ. Combination therapy with trastuzumab (Herceptin) and cisplatin for chemoresistant metastatic breast cancer: evidence for receptor-enhanced chemosensitivity. Semin Oncol. 1999;26(4 Suppl 12):89-95. Notes: Q2? PI PII FEW/N25 BC TRZ CHT IHC only.
Pelosi G, Scarpa A, Veronesi G, et al. A subset of high-grade pulmonary neuroendocrine carcinomas shows up-regulation of matrix metalloproteinase-7 associated with nuclear (beta)-catenin immunoreactivity, independent of EGFR and HER-2 gene amplification or expression. Virchows Arch. 2005;447(6):969-77. Notes: Q5 CS N50 LC IHC. [pmid: 16158183].
Peng JH, Zhu CD, Shen YL, et al. [Study on the expression of C-erbB-2 gene in coal miners with pneumoconiosis complicated by pulmonary cancer]. Zhonghua Lao Dong Wei Sheng Zhi Ye Bing Za Zhi. 2003;21(3):169-71. Notes: Q5 CS N25 LC IHC. [pmid: 14761474].
Perez EA, Geeraerts L, Suman VJ, et al. A randomized phase II study of sequential docetaxel and doxorubicin/cyclophosphamide in patients with metastatic breast cancer. Ann Oncol. 2002;13(8):1225-35. Notes: Q4? PII RCT N25 BC CHT ELS. [pmid: 12181246].
Perez EA, Suman VJ, Davidson NE, et al. HER2 testing by local, central, and reference laboratories in specimens from the North Central Cancer Treatment Group N9831 intergroup adjuvant trial. J Clin Oncol. 2006;24(19):3032-8. Notes: Q1? Q2? Q3A? DAC RCT N100 BC TRZ CHT IHC FIS. [pmid: 16809727].
Pestalozzi BC, Zahrieh D, Price KN, et al. Identifying breast cancer patients at risk for Central Nervous System (CNS) metastases in trials of the International Breast Cancer Study Group (IBCSG). Ann Oncol. 2006;17(6):935-44. Notes: Q3AB CS N100 BC HM?. [pmid: 16603601].
Petit T, Borel C, Ghnassia JP, et al. Chemotherapy response of breast cancer depends on HER-2 status and anthracycline dose intensity in the neoadjuvant setting. Clin Cancer Res. 2001;7(6):1577-81. Notes: Q3A? D? N50 BC CHT IHC. [pmid: 11410493].
Petit T, Wilt M, Velten M, et al. Comparative value of tumour grade, hormonal receptors, Ki-67, HER-2 and topoisomerase II alpha status as predictive markers in breast cancer patients treated with neoadjuvant anthracycline-based chemotherapy. Eur J Cancer. 2004;40(2):205-11. Notes: Q1? Q3A? D? N100 BC CHT IHC PCR. [pmid: 14728934].
Pichon MF, Hacene K, Guepratte S, Neumann R. Serum HER-2 extracellular domain (ECD) before the first metastasis in 128 breast cancer patients. Clin Lab. 2004;50(34):163-70. Notes: Q4? RET N100 BC T? O? ELS. [pmid: 15074470].
Pinto D, Pereira D, Portela C, da Silva JL, Lopes C, Medeiros R. The influence of HER2 genotypes as molecular markers in ovarian cancer outcome. Biochem Biophys Res Commun. 2005;335(4):1173-8. Notes: Q5 CS N100 OC HM?. [pmid: 16112085].
Piyathilake CJ, Frost AR, Manne U, et al. Differential expression of growth factors in squamous cell carcinoma and precancerous lesions of the lung. Clin Cancer Res. 2002;8(3):734-44. Notes: Q5 CS N50 LC IHC. [pmid: 11895903].
Plosker GL, Keam SJ. Trastuzumab: A review of its use in the management of HER2-positive metastatic and early-stage breast cancer. Drugs. 2006;66(4):449-75. Notes: NRA Q2?. [pmid: 16597163].
Pollan M, Varela G, Torres A, et al. Clinical value of p53, c-erbB-2, CEA and CA125 regarding relapse, metastasis and death in resectable non-small cell lung cancer. Int J Cancer. 2003;107(5):781-90. Notes: Q5 CS N100 LC IHC. [pmid: 14566828].
Potti A, Willardson J, Forseen C, et al. Predictive role of HER-2/neu overexpression and clinical features at initial presentation in patients with extensive stage small cell lung carcinoma. Lung Cancer. 2002;36(3):257-61. Notes: Q5 RET CS N100 LC. [pmid: 12009234].
Price N, Belani C. Clinical development of gefitinib in non-small-cell lung cancer and the Iressa Survival Evaluation in Lung Cancer trial. Clin Lung Cancer. 2005;6(4):214-6. Notes: Q5? NRA NPD LC. [pmid: 15694012].
Price N, Reddy GK. 2004 highlights from: 40th Annual Meeting of the American Society of Clinical Oncology, New Orleans, Louisiana, June 2004. Clin Lung Cancer. 2004;6(1):11-6. Notes: Q5? NRA NPD LC. [pmid: 15310411].
Prisack HB, Karreman C, Modlich O, et al. Predictive biological markers for response of invasive breast cancer to anthracycline/cyclophosphamide-based primary (radio-)chemotherapy. Anticancer Res. 2005;25(6C):4615-21. Notes: Q3A? RET N100 BC CHT HM?. [pmid: 16334152].
Pritchard KI. Use of ErbB-1 and ErbB-2 to select endocrine therapy for breast cancer: Will it play in peoria?. J Clin Oncol. 2001;19(18):3795-7. Notes: Q3B?. [pmid: 11559715].
Pupa SM, Menard S, Morelli D, Pozzi B, De Palo G, Colnaghi MI. The extracellular domain of the c-erbB-2 oncoprotein is released from tumor cells by proteolytic cleavage. Oncogene. 1993;8(11):2917-23. Notes: Q4? D? N? BC T? O? ELS. [pmid: 8105438].
Quaranta M, Daniele A, Coviello M, et al. c-erbB-2 protein level in tissue and sera of breast cancer patients: a possibly useful clinical correlation. Tumori. 2006;92(4):311-7. Notes: Q4? PRO? N100 BC T? IHC ELS. [pmid: 17036522].
Quddus RM, Sung JC, Zhang C, Pasqueriello T, Eklund M, Steinhoff MM. HER-2/neu expression in locally advanced breast carcinomas: pre-and post-neoadjuvant chemotherapy. Breast Cancer. 2005;12(4):294-8. Notes: Q3A? QEX? N50 BC CHT IHC. [pmid: 16286910].
Raff JP, Rajdev L, Malik U, et al. Phase II study of weekly docetaxel alone or in combination with trastuzumab in patients with metastatic breast cancer. Clin Breast Cancer. 2004;4(6):420-7. Notes: Q2 PII BC. [pmid: 15023243].
Rahko E, Blanco G, Soini Y, Bloigu R, Jukkola A. A mutant TP53 gene status is associated with a poor prognosis and anthracycline-resistance in breast cancer patients. Eur J Cancer. 2003;39(4):447-53. Notes: Q3A? RET? N50 BC CHT IHC. [pmid: 12751374].
Raybaud-Diogene H, Fortin A, Morency R, Roy J, Monteil RA, Tetu B. Markers of radioresistance in squamous cell carcinomas of the head and neck: a clinicopathologic and immunohistochemical study. J Clin Oncol. 1997;15(3):1030-8. Notes: Q5 CS N100 HNC IHC. [pmid: 9060543].
Regitnig P, Schippinger W, Lindbauer M, Samonigg H, Lax SF. Change of HER-2/neu status in a subset of distant metastases from breast carcinomas. J Pathol. 2004;203(4):918-26. Notes: Q4? PRO N25 BC T? IHC (primary versus lymph node versus mets) ELS. [pmid: 15258994].
Reinmuth N, Brandt B, Kunze WP, et al. Ploidy, expression of erbB1, erbB2, P53 and amplification of erbB1, erbB2 and erbB3 in non-small cell lung cancer. Eur Respir J. 2000;16(5):991-6. Notes: Q5 CS N100 LC PCR. [pmid: 11153605].
Revillion F, Hebbar M, Bonneterre J, Peyrat JP. Plasma c-erbB2 concentrations in relation to chemotherapy in breast cancer patients. Eur J Cancer. 1996;32A(2):231-4. Notes: Q4? D? N25 BC CHT ELS. [pmid: 8664033].
Riener EK, Arnold N, Kommoss F, Lauinger S, Pfisterer J. The prognostic and predictive value of immunohistochemically detected HER-2/neu overexpression in 361 patients with ovarian cancer: a multicenter study. Gynecol Oncol. 2004;95(1):89-94. Notes: Q5 CS N? OC IHC. [pmid: 15385115].
Risio M, Casorzo L, Redana S, Montemurro F. HER2 gene-amplified breast cancers with monosomy of chromosome 17 are poorly responsive to trastuzumab-based treatment. Oncol Rep. 2005;13(2):305-9. Notes: Q2? RET? N25 BC TRZ FIS. [pmid: 15643516].
Robinson AG, Turbin D, Thomson T, et al. Molecular predictive factors in patients receiving trastuzumab-based chemotherapy for metastatic disease. Clin Breast Cancer. 2006;7(3):254-61. Notes: Q2? RET N100 BC TRZ HM?. [pmid: 16942643].
Rodenhuis S, Bontenbal M, van Hoesel QG, et al. Efficacy of high-dose alkylating chemotherapy in HER2/neu-negative breast cancer. Ann Oncol. 2006;17(4):588-96. Notes: Q3A RCT N100 BC CHT (HDC) IHC+CIS conventional-dose arm may be useful if combine data on HER2- from this paper with data on HER2+ from same study in rec #480; also see original NEJM paper from Rodenhuis et al.: NEJM 2003; 349(1):7–16. CORPORATE NAME: Netherlands Working Party on Autologous Transplantation in Solid Tumours. [pmid: 16446318].
Rodrigo JP, Ramos S, Lazo PS, Alvarez I, Suarez C. Amplification of ERBB oncogenes in squamous cell carcinomas of the head and neck. EUR J CANCER PART A. 1996;32(11):2004-10. Notes: Q5 CS N50 HNC PCR.
Rody A, Karn T, Gatje R, et al. Gene expression profiles of breast cancer obtained from core cut biopsies before neoadjuvant docetaxel, adriamycin, and cyclophoshamide chemotherapy correlate with routine prognostic markers and could be used to identify predictive signatures. Zentralbl Gynakol. 2006;128(2):76-81. Notes: Q1? Q3A? PRO N50 BC CHT IHC FIS? OTH (gene expression profile). [pmid: 16673249].
Ross JS, Fletcher JA, Bloom KJ, et al. Targeted therapy in breast cancer: the HER-2/neu gene and protein. Mol Cell Proteomics. 2004;3(4):379-98. Notes: NRA Q1? Q2? Q3A? Q3B?. [pmid: 14762215].
Ross JS, Yang F, Kallakury BV, Sheehan CE, Ambros RA, Muraca PJ. HER-2/neu oncogene amplification by fluorescence in situ hybridization in epithelial tumors of the ovary. Am J Clin Pathol. 1999;111(3):311-6. Notes: Q5 CS N50 OC. [pmid: 10078105].
Roychowdhury DF, Tseng A Jr, Fu KK, Weinburg V, Weidner N. New prognostic factors in nasopharyngeal carcinoma. Tumor angiogenesis and C-erbB2 expression. Cancer. 1996;77(8):1419-26. Notes: Q5 RET CS N25 HNC IHC. [pmid: 8608524].
Rozan S, Vincent-Salomon A, Zafrani B, et al. No significant predictive value of c-erbB-2 or p53 expression regarding sensitivity to primary chemotherapy or radiotherapy in breast cancer. Int J Cancer. 1998;79(1):27-33. Notes: Q3A RET N100 BC CHT IHC. [pmid: 9495354].
Rubin SC, Finstad CL, Wong GY, Almadrones L, Plante M, Lloyd KO. Prognostic significance of HER-2/neu expression in advanced epithelial ovarian cancer: a multivariate analysis. Am J Obstet Gynecol. 1993;168(1 Pt 1):162-9. Notes: Q5 CS N100 OC IHC. [pmid: 8093588].
Safran H, DiPetrillo T, Nadeem A, et al. Trastuzumab, paclitaxel, cisplatin, and radiation for adenocarcinoma of the esophagus: a phase I study. Cancer Invest. 2004;22(5):670-7. Notes: Q5 PI N25 HNC. [pmid: 15581047].
Saghatchian M, Guepratte S, Hacene K, Neumann R, Floiras JL, Pichon MF. Serum HER-2 extracellular domain: relationship with clinicobiological presentation and prognostic value before and after primary treatment in 701 breast cancer patients. Int J Biol Markers. 2004;19(1):14-22. Notes: Q4? RET N100 BC T? ELS. [pmid: 15077922].
Sakamoto H. Molecular biology of multidrug resistance (MDR) in ovarian cancers and novel method of detecting developing MDR in vitro. Acta Obstet Gynaecol Jpn. 1999;51(8):549-61. Notes: Q5 CS N50 OC HM?.
Salvadori B, Pinzani P, Distante V, et al. Comparison of pre- and postsurgical concentrations of blood HER-2 mRNA and HER-2 extracellular domain reflects HER-2 status in early breast cancer. Clin Chem. 2005;51(1):254-6. Notes: Q4?. [pmid: 15613726].
Sanchez De Cos Escuin J. [New therapeutic targets and strategies in lung cancer]. Arch Bronconeumol. 2002;38(8):386-91. Notes: Q5? D? LC. [pmid: 12199921].
Sandri MT, Johansson HA, Zorzino L, et al. Serum EGFR and serum HER-2/neu are useful predictive and prognostic markers in metastatic breast cancer patients treated with metronomic chemotherapy. Cancer. 2007;110(3):509-17. Notes: Q4? PRO N100 BC CHT ELS. [pmid: 17559147].
Sato N, Sano M, Tabei T, et al. Combination docetaxel and trastuzumab treatment for patients with HER-2-overexpressing metastatic breast cancer: a multicenter, phase-II study. Breast Cancer. 2006;13(2):166-71. Notes: Q2? Q3A? PRO N25 BC TRZ CHT IHC FIS confirmation for IHC2+. [pmid: 16755112].
Sawaki M, Ito Y, Tada K, et al. Efficacy and safety of trastuzumab as a single agent in heavily pretreated patients with HER-2/neu-overexpressing metastatic breast cancer. Tumori. 2004;90(1):40-3. Notes: Q2? RET N50 BC TRZ IHC. [pmid: 15143970].
Scambia G, Benedetti Panici P, Ferrandina G, et al. Expression of HER-2/neu oncoprotein, DNA-ploidy and S-phase fraction in advanced ovarian cancer. Int J Gynecol Cancer. 1993;3(5):271-8. Notes: Q5 CS N50 OC IHC?. [pmid: 11578357].
Scambia G, Panici PB, Ferrandina G, et al. Expression of HER-2/neu oncoprotein, DNA-ploidy and S-phase fraction in advanced ovarian cancer. INT J GYNECOL CANCER. 1993;3(5):271-8. Notes: Q5 CS N50 OC IHC. [pmid: 11578357].
Schindlbeck C, Janni W, Schaffer P, et al. Biological factors of primary breast cancer tissue and “minimal residual disease”: TUMORBIOLOGIE DES PRIMAREN MAMMAKARZINOMS UND DER MINIMALEN RESTERKRANKUNG. Acta Med Austriaca. 2002;29(SUPPL. 59):27-31. Notes: Q3A? D? N100 BC CHT IHC?.
Schindlbeck C, Janni W, Schaffer P, et al. [Tumor biology of primary breast cancer and minimal residual disease]. Acta Med Austriaca Suppl. 2002;59:27-31. Notes: Q3A? D? N100 BC CHT IHC?. [pmid: 12506757].
Schindlbeck C, Janni W, Shabani N, et al. Isolated tumor cells in the bone marrow (ITC-BM) of breast cancer patients before and after anthracyclin based therapy: influenced by the HER2- and Topoisomerase IIalpha-status of the primary tumor?. J Cancer Res Clin Oncol. 2005;131(8):539-46. Notes: Q1? Q3A? D? N50 BC CHT IHC FIS. [pmid: 15887027].
Schippinger W, Regitnig P, Bauernhofer T, et al. The course of serum HER-2/neu levels as an independent prognostic factor for survival in metastatic breast cancer. Oncol Rep. 2004;11(6):1331-6. Notes: Q4? PRO? N100 BC T? ELS. [pmid: 15138574].
Schmidt M, Bachhuber A, Victor A, et al. p53 expression and resistance against paclitaxel in patients with metastatic breast cancer. J Cancer Res Clin Oncol. 2003;129(5):295-302. Notes: Q3A N25 PRO? BC CHT IHC. [pmid: 12715164].
Schneeweiss A, Goerner R, Hensel MA, et al. Tandem high-dose chemotherapy in high-risk primary breast cancer: a multivariate analysis and a matched-pair comparison with standard-dose chemotherapy. Biol Blood Marrow Transplant. 2001;7(6):332-42. Notes: Q3A? RET? QEX? N100 BC CHT HDC HM?. [pmid: 11464976].
Schneeweiss A, Schuetz F, Rudlowski C, et al. Dose-dense primary systemic chemotherapy with gemcitabine plus epirubicin sequentially followed by docetaxel for early breast cancer: final results of a phase I/II trial. Anticancer Drugs. 2005;16(9):1023-8. Notes: Q3 PI PII N50 BC. [pmid: 16162980].
Schneider J, Gonzalez-Roces S, Pollan M, et al. Expression of LRP and MDR1 in locally advanced breast cancer predicts axillary node invasion at the time of rescue mastectomy after induction chemotherapy. Breast Cancer Res. 2001;3(3):183-91. Notes: Q3A? RET N50 BC CHT IHC. [pmid: 11305953]. [pmcid: 30705].
Schneider J, Lucas R, Sanchez J, Ruibal A, Tejerina A, Martin M. Modulation of molecular marker expression by induction chemotherapy in locally advanced breast cancer: correlation with the response to therapy and the expression of MDR1 and LRP. Anticancer Res. 2000;20(6B):4373-7. Notes: Q3A? RET N25 BC CHT IHC. [pmid: 11205274].
Schneider PM, Praeuer HW, Stoeltzing O, et al. Multiple molecular marker testing (p53, C-Ki-ras, c-erbB-2) improves estimation of prognosis in potentially curative resected non-small cell lung cancer. Br J Cancer. 2000;83(4):473-9. Notes: Q5 CS N100 LC IHC. [pmid: 10945494].
Schonborn I, Zschiesche W, Spitzer E, et al. C-erbB-2 overexpression in primary breast cancer: independent prognostic factor in patients at high risk. Breast Cancer Res Treat. 1994;29(3):287-95. Notes: Q5 CS N100 BC. [pmid: 7914107].
Schulze G. HER-2/neu gene product in serum—an oncoprotein in the diagnosis and therapy of breast carcinoma. Anticancer Res. 2003;23(2A):1007-10. Notes: NRA Q4?. [pmid: 12820339].
Schwartz MK, Smith C, Schwartz DC, Dnistrian A, Neiman I. Monitoring therapy by serum HER-2/neu. Int J Biol Markers. 2000;15(4):324-9. Notes: Q4? D? N? BC T? ELS. [pmid: 11192828].
Seidman AD, Fornier MN, Esteva FJ, et al. Weekly trastuzumab and paclitaxel therapy for metastatic breast cancer with analysis of efficacy by HER2 immunophenotype and gene amplification. J Clin Oncol. 2001;19(10):2587-95. Notes: Q1? Q2? Q3A? PII N50 BC TRZ CHT MAB FIS. [pmid: 11352950].
Seki A, Yoshinouchi M, Seki N, Kodama J, Miyagi Y, Kudo T. Detection of c-erbB-2 and FGF-3 (INT-2) gene amplification in epithelial ovarian cancer. Int J Oncol. 2000;17(1):103-6. Notes: Q5 CS N25 OC HM?. [pmid: 10853025].
Selvaggi G, Scagliotti GV, Torri V, et al. HER-2/neu overexpression in patients with radically resected nonsmall cell lung carcinoma. Impact on long-term survival. Cancer. 2002;94(10):2669-74. Notes: Q5 CS N100 LC IHC. [pmid: 12173335].
Sezgin C, Karabulut B, Uslu R, et al. Potential predictive factors for response to weekly paclitaxel treatment in patients with metastatic breast cancer. J Chemother. 2005;17(1):96-103. Notes: Q3A? RET? N25 BC CHT IHC. [pmid: 15828451].
Sharma S, Saboorian HM, Frawley WH, Frenkel EP, Haley BB, Ashfaq R. MIB1 labeling index as an indicator of chemoresponse in carcinoma of the breast. Appl Immunohistochem Mol Morphol. 2004;12(4):290-5. Notes: Q3A? RET N50 BC CHT IHC (core biopsy versus surgical specimen; response to pre-operative chemoTx). [pmid: 15536327].
Shepherd FA, Tsao MS. Unraveling the mystery of prognostic and predictive factors in epidermal growth factor receptor therapy. J Clin Oncol. 2006;24(7):1219-20. author reply 1220–1. Notes: Q5? COM LTR LC. [pmid: 16505443].
Shiga H, Heath EI, Rasmussen AA, et al. Prognostic value of p53, glutathione S-transferase pi, and thymidylate synthase for neoadjuvant cisplatin-based chemotherapy in head and neck cancer. Clin Cancer Res. 1999;5(12):4097-104. Notes: Q5 CS N50 LC IHC. [pmid: 10632346].
Shin DM, Donato NJ, Perez-Soler R, et al. Epidermal growth factor receptor-targeted therapy with C225 and cisplatin in patients with head and neck cancer. Clin Cancer Res. 2001;7(5):1204-13. Notes: Q5? PI FEW HNC NRS (HOMOG HER2). [pmid: 11350885].
Shnayder Y, Kuriakose MA, Yee H, et al. Adhesion molecules as prognostic factors in nasopharyngeal carcinoma. Laryngoscope. 2001;111(10):1842-6. Notes: Q5 CS N50 HNC IHC. [pmid: 11801955].
Shrestha P, Huang JW, Tsuji T, et al. Rare expression of the c-erbB-2 oncoprotein in salivary gland tumors: an immunohistochemical study. J Oral Pathol Med. 1992;21(10):477-80. Notes: Q5 CS N100 HNC IHC. [pmid: 1361005].
Sias PE, Kotts CE, Vetterlein D, Shepard M, Wong WL. ELISA for quantitation of the extracellular domain of p185HER2 in biological fluids. J Immunol Methods. 1990;132(1):73-80. Notes: Q4? D? N? T? O? ELS. [pmid: 1975263].
Singleton TP, Perrone T, Oakley G, et al. Activation of c-erbB-2 and prognosis in ovarian carcinoma. Comparison with histologic type, grade, and stage. Cancer. 1994;73(5):1460-6. Notes: Q5 CS N50 OC HM?. [pmid: 7906608].
Sjogren S, Inganas M, Lindgren A, Holmberg L, Bergh J. Prognostic and predictive value of c-erbB-2 overexpression in primary breast cancer, alone and in combination with other prognostic markers. J Clin Oncol. 1998;16(2):462-9. Notes: Q3B? RET N? BC HT IHC. [pmid: 9469329].
Sjostrom J, Collan J, von Boguslawski K, et al. C-erbB-2 expression does not predict response to docetaxel or sequential methotrexate and 5-fluorouracil in advanced breast cancer. Eur J Cancer. 2002;38(4):535-42. Notes: Q3A? RCT N100 BC CHT IHC (no reflex FISH and IHC 2+ considered HER2+). [pmid: 11872346].
Skirnisdottir I, Seidal T, Karlsson MG, Sorbe B. Clinical and biological characteristics of clear cell carcinomas of the ovary in FIGO stages I–II. Int J Oncol. 2005;26(1):177-83. Notes: Q5 RET CS N100 OC IHC. [pmid: 15586238].
Slamon DJ, Leyland-Jones B, Shak S, et al. Use of chemotherapy plus a monoclonal antibody against HER2 for metastatic breast cancer that overexpresses HER2. N Engl J Med. 2001;344(11):783-92. Notes: Q2? RCT N100 BC TRZ CHT IHC only. [pmid: 11248153].
Sonnweber B, Dlaska M, Skvortsov S, Dirnhofer S, Schmid T, Hilbe W. High predictive value of epidermal growth factor receptor phosphorylation but not of EGFRvIII mutation in resected stage I non-small cell lung cancer (NSCLC). J Clin Pathol. 2006;59(3):255-9. Notes: Q5 CS N50 LC IHC. [pmid: 16505275].
Soubeyran I, Quenel N, Coindre JM, et al. pS2 protein: a marker improving prediction of response to neoadjuvant tamoxifen in post-menopausal breast cancer patients. Br J Cancer. 1996;74(7):1120-5. Notes: Q3B? RET N100 BC HT IHC. [pmid: 8855985].
Soubeyran I, Quenel N, Mauriac L, Durand M, Bonichon F, Coindre JM. Variation of hormonal receptor, pS2, c-erbB-2 and GSTpi contents in breast carcinomas under tamoxifen: a study of 74 cases. Br J Cancer. 1996;73(6):735-43. Notes: Q3B? RET? N50 BC HT IHC. [pmid: 8611373].
Souder C, Leitzel K, Ali SM, et al. Serum epidermal growth factor receptor/HER-2 predicts poor survival in patients with metastatic breast cancer. Cancer. 2006;107(10):2337-45. Notes: Q4? RCT N100 BC HT ELS. [pmid: 17048231].
Spataro VJ, Litman H, Viale G, et al. Decreased immunoreactivity for p27 protein in patients with early-stage breast carcinoma is correlated with HER-2/neu overexpression and with benefit from one course of perioperative chemotherapy in patients with negative lymph node status: results from International Breast Cancer Study Group Trial V. Cancer. 2003;97(7):1591-600. Notes: Q3A? RCT? N100 BC CHT HM? CORPORATE NAME: International Breast Cancer Study Group. [pmid: 12655514].
Spector NL, Xia W, Burris H 3rd, et al. Study of the biologic effects of lapatinib, a reversible inhibitor of ErbB1 and ErbB2 tyrosine kinases, on tumor growth and survival pathways in patients with advanced malignancies. J Clin Oncol. 2005;23(11):2502-12. Notes: Q2? PRO FEW BC TRZ (lapatinib) HM?. [pmid: 15684311].
Stearns V, Singh B, Tsangaris T, et al. A prospective randomized pilot study to evaluate predictors of response in serial core biopsies to single agent neoadjuvant doxorubicin or paclitaxel for patients with locally advanced breast cancer. Clin Cancer Res. 2003;9(1):124-33. Notes: Q3A? RCT N25 BC CHT IHC. [pmid: 12538460].
Stein S, DeMichele A, Domchek S, Fox K. Gemcitabine and trastuzumab combinations for patients with metastatic breast cancer overexpressing HER2/neu. Clin Breast Cancer. 2004;4(SUPPL. 3):S117-S120. Notes: NRA Q2? Q3A? TRZ CHT. [pmid: 14754469].
Stenman G, Sandros J, Nordkvist A, Mark J, Sahlin P. Expression of the ERBB2 protein in benign and malignant salivary gland tumors. Genes Chromosomes Cancer. 1991;3(2):128-35. Notes: Q5 CS N50 HNC. [pmid: 1676907].
Streckfus C, Bigler L, Dellinger T, Dai X, Kingman A, Thigpen JT. The presence of soluble c-erbB-2 in saliva and serum among women with breast carcinoma: a preliminary study. Clin Cancer Res. 2000;6(6):2363-70. Notes: Q4? PRO? N25 BC T? ELS. [pmid: 10873088].
Sugano K, Kawai T, Ishii M, et al. [Clinical evaluation of serum ErbB-2 protein using enzyme immuno assay (ErbB-2 EIA. Gan To Kagaku Ryoho. 1994;21(8):1255-62. Notes: Q4? D? N100 BC T? O? ELS. [pmid: 7913313].
Sugano K, Kawai T, Ishii M, et al. [Clinical study of serum ErbB-2 protein using sandwich radioimmunometric assay (ErbB-2 IRMA ‘Eiken’)]. Gan To Kagaku Ryoho. 1994;21(8):1245-53. Notes: Q4? D? N100 BC T? O? ELS. [pmid: 7913312].
478 Sugano K, Ushiama M, Fukutomi T, Tsuda H, Kitoh T, Ohkura H. Combined measurement of the c-erbB-2 protein in breast carcinoma tissues and sera is useful as a sensitive tumor marker for monitoring tumor relapse. Int J Cancer. 2000;89(4):329-36. Notes: Q4? RET? N100 BC T? O? IHC ELS. [pmid: 10956406].
Surowiak P, Materna V, Kaplenko I, et al. Topoisomerase 1A, HER/2neu and Ki67 expression in paired primary and relapse ovarian cancer tissue samples. Histol Histopathol. 2006;21(79):713-20. Notes: Q5 CS N50 OC IHC. [pmid: 16598670].
Suzuki M, Shigematsu H, Iizasa T, et al. Exclusive mutation in epidermal growth factor receptor gene, HER-2, and KRAS, and synchronous methylation of nonsmall cell lung cancer. Cancer. 2006;106(10):2200-7. Notes: Q5 CS N25 LC HM?. [pmid: 16598760].
Szelachowska J, Jelen M. Laminin, Her2/neu and Ki-67 as prognostic factors in non-small cell lung cancer. Rocz Akad Med Bialymst. 2004;49:256-61. Notes: Q5 CS N50 LC HM?. [pmid: 15631353].
Takamura Y, Kobayashi H, Taguchi T, Motomura K, Inaji H, Noguchi S. Prediction of chemotherapeutic response by collagen gel droplet embedded culture-drug sensitivity test in human breast cancers. Int J Cancer. 2002;98(3):450-5. Notes: Q3A? PRO? N50 BC CHT IHC. [pmid: 11920599].
Takano T, Ohe Y, Sakamoto H, et al. Epidermal growth factor receptor gene mutations and increased copy numbers predict gefitinib sensitivity in patients with recurrent non-small-cell lung cancer. J Clin Oncol. 2005;23(28):6829-37. Notes: Q5 CS N25 LC PCR. [pmid: 15998907].
Tan D, Deeb G, Wang J, et al. HER-2/neu Protein Expression and Gene Alteration in Stage I–IIIA Non-Small-Cell Lung Cancer: A Study of 140 Cases Using a Combination of High Throughput Tissue Microarray, Immunohistochemistry, and Fluorescent In Situ Hybridization. Diagn Mol Pathol. 2003;12(4):201-11. Notes: Q5 CS N100 LC IHC. [pmid: 14639106].
Tanabe H, Nishii H, Sakata A, et al. Overexpression of HER-2/neu is not a risk factor in ovarian clear cell adenocarcinoma. Gynecol Oncol. 2004;94(3):735-9. Notes: Q5 CS N100 OC IHC. [pmid: 15350366].
Tantawy A, Youins L, Hamza M. Expression of c-erb B-2 oncoprotein in cancer of the larynx in relation to invasion of the cartilagenous framework and prognosis. Eur Arch Otorhinolaryngol. 1999;256(2):72-7. Notes: Q5 CS N25 HNC. [pmid: 10068894].
Tedesco KL, Thor AD, Johnson DH, et al. Docetaxel combined with trastuzumab is an active regimen in HER-2 3+ overexpressing and fluorescent in situ hybridization-positive metastatic breast cancer: a multi-institutional phase II trial. J Clin Oncol. 2004;22(6):1071-7. Notes: Q1? Q2? Q3A? PRO N25 BC TRZ CHT IHC FIS. [pmid: 15020608].
Tetu B, Brisson J. Prognostic significance of HER-2/neu oncoprotein expression in node-positive breast cancer. The influence of the pattern of immunostaining and adjuvant therapy. Cancer. 1994;73(9):2359-65. Notes: Q3A? Q3B? RET N100 BC CHT HT IHC. [pmid: 7909490].
Tetu B, Brisson J, Plante V, Bernard P. p53 and c-erbB-2 as markers of resistance to adjuvant chemotherapy in breast cancer. Mod Pathol. 1998;11(9):823-30. Notes: Q3A? RET N100 BC CHT IHC. [pmid: 9758361].
Thor AD, Berry DA, Budman DR, et al. erbB-2, p53, and efficacy of adjuvant therapy in lymph node-positive breast cancer. J Natl Cancer Inst. 1998;90(18):1346-60. Notes: Q3A? RCT? BC N100 CHT IHC. [pmid: 9747866].
Thuerigen O, Schneeweiss A, Toedt G, et al. Gene expression signature predicting pathologic complete response with gemcitabine, epirubicin, and docetaxel in primary breast cancer. J Clin Oncol. 2006;24(12):1839-45. Notes: Q3A? PI PII (pooled) N100 BC CHT HM? (no reflex FISH & IHC 2+ considered HER2-). [pmid: 16622258].
Tiseo M, Loprevite M, Ardizzoni A. Epidermal growth factor receptor inhibitors: a new prospective in the treatment of lung cancer. Curr Med Chem Anticancer Agents. 2004;4(2):139-48. Notes: Q5 NRA NPD LC. [pmid: 15032719].
Tokunaga E, Kataoka A, Kimura Y, et al. The association between Akt activation and resistance to hormone therapy in metastatic breast cancer. Eur J Cancer. 2006;42(5):629-35. Notes: Q3B? RET N25 BC HT HM?. [pmid: 16464571].
Tokunaga E, Kimura Y, Mashino K, et al. Activation of PI3K/Akt signaling and hormone resistance in breast cancer. Breast Cancer. 2006;13(2):137-44. Notes: Q3B? RET N100 BC HT HM?. [pmid: 16755107].
Tokunaga E, Kimura Y, Oki E, et al. Akt is frequently activated in HER2/neu-positive breast cancers and associated with poor prognosis among hormone-treated patients. Int J Cancer. 2006;118(2):284-9. Notes: Q3B? RET N100 BC HT HM?. [pmid: 16049961].
Tomic S, Ilic Forko J, Babic D, Sundov D, Kuret S, Andelinovic S. c-erbB-2, p53, and nm23 proteins as prognostic factors in patients with epithelial ovarian carcinoma. Croat Med J. 2003;44(4):429-34. Notes: Q5 CS N50 OC IHC. [pmid: 12950146].
Tomov S, Popovska S, Veselinova T, Gorchev G, Velkova A. [Immunohistochemical analysis of epidermal growth factor receptors expression in malignant ovarian tumors]. Akush Ginekol (Sofiia). 2005;44(Suppl 2):42-7. Notes: Q5 PRO CS N50 IHC OC. [pmid: 16028404].
Torrisi R, Colleoni M, Veronesi P, et al. Primary therapy with ECF in combination with a GnRH analog in premenopausal women with hormone receptor-positive T2–T4 breast cancer. Breast. 2007;16(1):73-80. Notes: Q3AB CS N25 CHT HT BC. [pmid: 16908152].
Tovey S, Dunne B, Witton CJ, Forsyth A, Cooke TG, Bartlett JM. Can molecular markers predict when to implement treatment with aromatase inhibitors in invasive breast cancer?. Clin Cancer Res. 2005;11(13):4835-42. Notes: Q3B? RET N100 BC HT IHC TMA. [pmid: 16000581].
Tse C, Brault D, Gligorov J, et al. Evaluation of the quantitative analytical methods real-time PCR for HER-2 gene quantification and ELISA of serum HER-2 protein and comparison with fluorescence in situ hybridization and immunohistochemistry for determining HER-2 status in breast cancer patients. Clin Chem. 2005;51(7):1093-101. Notes: Q1? Q4? RET N50 BC T? O? IHC FIS PCR ELS. [pmid: 15976096].
Tsutsui S, Ohno S, Murakami S, Hachitanda Y, Oda S. Prognostic value of c-erbB2 expression in breast cancer. J Surg Oncol. 2002;79(4):216-23. Notes: Q3A? Q3B? RET PRG N100 BC CHT HT IHC. [pmid: 11920778].
Turken O, Kunter E, Cermik H, et al. Prevalence and prognostic value of c-erbB2 expression in non-small cell lung cancer (NSCLC). Neoplasma. 2003;50(4):257-61. Notes: Q5 CS N50 LC IHC. [pmid: 12937837].
Tyagi P. Updated data from the Iressa survival in lung cancer trial. Clin Lung Cancer. 2005;6(6):340-2. Notes: Q5? D? LC. [pmid: 15943893].
Valverde JJ, Martin M, Garcia-Asenjo JA, Casado A, Vidart JA, Diaz-Rubio E. Prognostic value of DNA quantification in early epithelial ovarian carcinoma. Obstet Gynecol. 2001;97(3):409-16. Notes: Q5 CS N50 OC IHC. [pmid: 11239647].
Van der Zee AGJ, Hollema H, Suurmeijer AJH, et al. Value of P-glycoprotein, glutathione S-transferase pi, c-erbB-2, and p53 as prognostic factors in ovarian carcinomas. J CLIN ONCOL. 1995;13(1):70-8. Notes: Q5 CS N100 OC IHC. [pmid: 7799045].
Van Poznak C, Tan L, Panageas KS, et al. Assessment of molecular markers of clinical sensitivity to single-agent taxane therapy for metastatic breast cancer. J Clin Oncol. 2002;20(9):2319-26. Notes: Q3A? RET N100 BC CHT MAB. [pmid: 11981003].
Vargas-Roig LM, Gago FE, Tello O, Martin De Civetta MT, Ciocca DR. c-erbB-2 (HER-2/neu) protein and drug resistance in breast cancer patients treated with induction chemotherapy. Int J Cancer. 1999;84(2):129-34. Notes: Q3A? PRO N50 BC CHT IHC. [pmid: 10096243].
Verri E, Guglielmini P, Puntoni M, et al. HER2/neu oncoprotein overexpression in epithelial ovarian cancer: evaluation of its prevalence and prognostic significance. Clinical study. Oncology. 2005;68(23):154-61. Notes: Q5 RET CS N100 OC OTH. [pmid: 16020953].
Villman K, Sjostrom J, Heikkila R, et al. TOP2A and HER2 gene amplification as predictors of response to anthracycline treatment in breast cancer. Acta Oncol. 2006;45(5):590-6. Notes: Q3A? RET N50 BC CHT CIS. [pmid: 16864174].
Vincent-Salomon A, Carton M, Freneaux P, et al. ERBB2 overexpression in breast carcinomas: no positive correlation with complete pathological response to preoperative high-dose anthracycline-based chemotherapy. Eur J Cancer. 2000;36(5):586-91. Notes: Q3A? PRO? N50 BC CHT IHC. [pmid: 10738122].
Vincent-Salomon A, Jouve M, Genin P, et al. HER2 status in patients with breast carcinoma is not modified selectively by preoperative chemotherapy and is stable during the metastatic process. Cancer. 2002;94(8):2169-73. Notes: Q3A? PRO? N100 BC CHT IHC. [pmid: 12001113].
Visco V, Bei R, Moriconi E, Gianni W, Kraus MH, Muraro R. ErbB2 immune response in breast cancer patients with soluble receptor ectodomain. Am J Pathol. 2000;156(4):1417-24. Notes: Q4? RET? N50 BC T? O? ELS?. [pmid: 10751365]. [pmcid: 1876881].
Vogel CL, Cobleigh MA, Tripathy D, et al. Efficacy and safety of trastuzumab as a single agent in first-line treatment of HER2-overexpressing metastatic breast cancer. J Clin Oncol. 2002;20(3):719-26. Notes: Q2? RCT N100 BC TRZ IHC FIS. [pmid: 11821453].
Vogel CL, Cobleigh MA, Tripathy D, et al. First-line Herceptin monotherapy in metastatic breast cancer. Oncology. 2001;61(Suppl 2):37-42. Notes: Q2? RCT N100 BC TRZ IHC FIS. [pmid: 11694786].
Volas GH, Leitzel K, Teramoto Y, Grossberg H, Demers L, Lipton A. Serial serum c-erbB-2 levels in patients with breast carcinoma. Cancer. 1996;78(2):267-72. Notes: Q4? PRO N100 BC HT ELS. [pmid: 8674002].
Volm M, Drings P, Wodrich W. Prognostic significance of the expression of c-fos, c-jun and c-erbB-1 oncogene products in human squamous cell lung carcinomas. J Cancer Res Clin Oncol. 1993;119(9):507-10. Notes: Q5 CS N100 LC IHC. [pmid: 8100821].
Voss A, Neumann R. Serum HER-2/neu: a new predictive marker. Int J Clin Pharmacol Ther. 2002;40(12):584-5. Notes: Q4?. [pmid: 12503824].
Walshe JM, Denduluri N, Berman AW, Rosing DR, Swain SM. A phase II trial with trastuzumab and pertuzumab in patients with HER2-overexpressed locally advanced and metastatic breast cancer. Clin Breast Cancer. 2006;6(6):535-9. Notes: Q2?. [pmid: 16595039].
Wang J, Buchholz TA, Middleton LP, et al. Assessment of histologic features and expression of biomarkers in predicting pathologic response to anthracycline-based neoadjuvant chemotherapy in patients with breast carcinoma. Cancer. 2002;94(12):3107-14. Notes: Q3A? D? N50 BC CHT HM?. [pmid: 12115341].
Wang SE, Narasanna A, Perez-Torres M, et al. HER2 kinase domain mutation results in constitutive phosphorylation and activation of HER2 and EGFR and resistance to EGFR tyrosine kinase inhibitors. Cancer Cell. 2006;10(1):25-38. Notes: Q5 CS N? LC. [pmid: 16843263].
Wang Y, Kristensen GB, Helland A, Nesland JM, Borresen-Dale AL, Holm R. Protein expression and prognostic value of genes in the erb-b signaling pathway in advanced ovarian carcinomas. Am J Clin Pathol. 2005;124(3):392-401. Notes: Q5 CS N100 OC HM?. [pmid: 16191507].
Wang Y, Zhang XR, Fu J, Tan W, Zhang W. [Prognostic value of expression of FASE, HER-2/neu, bcl-2 and p53 in stage I non-small cell lung cancer]. Zhonghua Zhong Liu Za Zhi. 2004;26(6):369-72. Notes: Q5 CS N50 LC IHC. [pmid: 15312350].
Wang ZR, Liu W, Smith ST, Parrish RS, Young SR. c-myc and chromosome 8 centromere studies of ovarian cancer by interphase. FISH Exp Mol Pathol. 1999;66(2):140-8. Notes: Q5 CS N25 OC FIS.
Watanabe N, Miyamoto M, Tokuda Y, et al. Serum c-erbB-2 in breast cancer patients. Acta Oncol. 1994;33(8):901-4. Notes: Q4? D? N100 BC T? O? els. [pmid: 7818922].
Weed DT, Gomez-Fernandez C, Pacheco J, et al. MUC4 and ERBB2 expression in major and minor salivary gland mucoepidermoid carcinoma. Head Neck. 2004;26(4):353-64. Notes: Q5 RET CS N25 HNC HNC IHC. [pmid: 15054739].
Weed DT, Gomez-Fernandez C, Yasin M, et al. MUC4 and ErbB2 expression in squamous cell carcinoma of the upper aerodigestive tract: correlation with clinical outcomes. Laryngoscope. 2004;114(8 Pt 2 Suppl 101):1-32. Notes: Q5 RET CS N100 HNC IHC. [pmid: 15284539].
Weinstein GS, Nuamah IF, Tucker J, Montone K. Evaluation of HER-2/neu (c-erbB-2) oncogene expression in whole organ sections of supraglottic squamous cell carcinoma. Ann Otol Rhinol Laryngol. 1996;105(4):275-9. Notes: Q5 CS N100 HNC IHC. [pmid: 8604888].
Weiss J, Friedrich MG. [Prostate carcinoma: higher COX-2 contents in advanced tumors]. Aktuelle Urol. 2004;35(5):359-61. Notes: Q5? D? PC. [pmid: 15383996].
Wild PJ, Reichle A, Andreesen R, et al. Microsatellite instability predicts poor short-term survival in patients with advanced breast cancer after high-dose chemotherapy and autologous stem-cell transplantation. Clin Cancer Res. 2004;10(2):556-64. Notes: Q3A? RET N25 BC CHT (HDC) IHC. [pmid: 14760077].
Willems A, Gauger K, Henrichs C, Harbeck N. Antibody therapy for breast cancer. Anticancer Res. 2005;25(3A):1483-9. Notes: Q2? NRA. [pmid: 16033049].
Willsher PC, Beaver J, Pinder S, et al. Prognostic significance of serum c-erbB-2 protein in breast cancer patients. Breast Cancer Res Treat. 1996;40(3):251-5. Notes: Q4? RET? N100 BC HT ELS (+IHC). [pmid: 8883967].
Willsher PC, Pinder SE, Gee JMW, et al. c-erbB2 expression predicts response to preoperative chemotherapy for locally advanced breast cancer. Anticancer Res. 1998;18(5 B):3695-8. Notes: Q3A? RET? N50 BC CHT IHC. [pmid: 9854479].
Witzel I, Thomssen C, Krenkel S, et al. Clinical utility of determination of HER-2/neu and EGFR fragments in serum of patients with metastatic breast cancer. Int J Biol Markers. 2006;21(3):131-40. Notes: Q4? D? N50 BC T? IHC ELS. [pmid: 17013794].
Wolf D, Wolf AM, Rumpold H, et al. The expression of the regulatory T cell-specific forkhead box transcription factor FoxP3 is associated with poor prognosis in ovarian cancer. Clin Cancer Res. 2005;11(23):8326-31. Notes: Q5 CS N50 OC RNA. [pmid: 16322292].
Wolf M. [Prognostic factors and therapeutic strategy in non-small-cell bronchial carcinoma]. Schweiz Rundsch Med Prax. 1997;86(42):1640-6. Notes: Q5 CS N? LC HM?.
Wright C, Nicholson S, Angus B, et al. Relationship between c-erbB-2 protein product expression and response to endocrine therapy in advanced breast cancer. Br J Cancer. 1992;65(1):118-21. Notes: Q3B? RET N50 BC HT HM?. [pmid: 1346366].
Wu JT, Astill ME, Gagon SD, Bryson L. Measurement of c-erbB-2 proteins in sera from patients with carcinomas and in breast tumor tissue cytosols: correlation with serum tumor markers and membrane-bound oncoprotein. J Clin Lab Anal. 1995;9(3):151-65. Notes: Q4? Q5? D? N? BC PC OVC T? ELS (serum and tissue cytosol). [pmid: 7541455].
Wu Y, Khan H, Chillar R, Vadgama JV. Prognostic value of plasma HER-2/neu in African American and Hispanic women with breast cancer. Int J Oncol. 1999;14(6):1021-37. Notes: Q4? D? N? BC T? ELS. [pmid: 10339653].
Xia W, Lau YK, Zhang HZ, et al. Strong correlation between c-erbB-2 overexpression and overall survival of patients with oral squamous cell carcinoma. Clin Cancer Res. 1997;3(1):3-9. Notes: Q5 CS N50 HNC HM?. [pmid: 9815530].
Xu Y, Yao L, Ouyang T, et al. p53 Codon 72 polymorphism predicts the pathologic response to neoadjuvant chemotherapy in patients with breast cancer. Clin Cancer Res. 2005;11(20):7328-33. Notes: Q3A? D? N100 BC CHT (neoadj) IHC (HER2+ = IHC 2+ or 3+, without reflex FISH for 2+). [pmid: 16243804].
Yamashita H, Toyama T, Nishio M, et al. p53 protein accumulation predicts resistance to endocrine therapy and decreased post-relapse survival in metastatic breast cancer. Breast Cancer Res. 2006;8(4):R48. Notes: Q3A? RET N50 BC HT IHC. [pmid: 16869955].
Yan J, Fang Y, Huang BJ, Liang QW, Wu QL, Zeng YX. Absence of evidence for HER2 amplification in nasopharyngeal carcinoma. Cancer Genet Cytogenet. 2002;132(2):116-9. Notes: Q5 CS N25 HNC. [pmid: 11850071].
Yan Y, Guo Q, Nan P. [Relationship between c-erbB-2 oncoprotein expression and prognosis in salivary gland malignant pleomorphic adenoma]. Zhonghua Kou Qiang Yi Xue Za Zhi 1995; 30(6):326–8, 383. Notes: Q5 CS N50 HNC IHC
Yang H, Zhang G, Xu K. [c-erbB2 gene amplification in human primary epithelial ovarian cancer and its clinical significance]. Zhonghua Zhong Liu Za Zhi. 1998;20(5):367-70. Notes: Q5 CS N100 OC SB. [pmid: 10921034].
Yano S, Muguruma H, Sone S. [Molecular targetting therapy for non-small-cell lung neoplasms with EGF-R inhibitors]. Nippon Naika Gakkai Zasshi. 2003;92(2):318-23. Notes: Q5? D? LC. [pmid: 12652739].
Yasasever V, Dincer M, Camlica H, Duranyildiz D, Dalay N. Serum c-erb B2 oncoprotein levels are elevated in recurrent and metastatic breast cancer. Clin Biochem. 2000;33(4):315-7. Notes: Q4?. [pmid: 10936592].
Yasui W, Nishiyama M, Tsuruo T, Tahara E. Molecular targeting therapy for cancer: the Twelfth International Symposium of the Hiroshima Cancer Seminar, November 2002. Cancer Sci. 2003;94(2):221-3. Notes: Q5? D? LC. [pmid: 12708501].
Yoo GH, Hung MC, Lopez-Berestein G, et al. Phase I trial of intratumoral liposome E1A gene therapy in patients with recurrent breast and head and neck cancer. Clin Cancer Res. 2001;7(5):1237-45. Notes: Q5 PI FEW BC. [pmid: 11350889].
Yu CJ, Shun CT, Yang PC, et al. Sialomucin expression is associated with erbB-2 oncoprotein overexpression, early recurrence, and cancer death in non-small-cell lung cancer. Am J Respir Crit Care Med. 1997;155(4):1419-27. Notes: Q5 CS N100 LC IHC. [pmid: 9105088].
Yu FZ, Sugano K, Ohkura H, Mori S. [Development of sandwich radioimmunometric assay for serum c-erbB-2 oncogene product and its significance in diagnosing breast carcinoma]. Rinsho Byori. 1991;39(10):1087-92. Notes: Q4? D? N? BC T? O? ELS. [pmid: 1684826].
Yuan P, Xu BH, Chu DT. Correlation between serum HER-2 oncoprotein and patients with breast cancer. Chin Med Sci J. 2004;19(3):212-5. Notes: Q4? RET? N50 T? ELS. [pmid: 15506651].
Yuan P, Xu BH, Zhang C, Qi J. [Serum her-2/neu level and related factors in patients with breast cancer]. Zhonghua Zhong Liu Za Zhi. 2003;25(6):573-4. Notes: Q4? RET? N50 T? ELS. [pmid: 14690565].
Zhu L, Chow LW, Loo WT, Guan XY, Toi M. Her2/neu expression predicts the response to antiaromatase neoadjuvant therapy in primary breast cancer: subgroup analysis from celecoxib antiaromatase neoadjuvant trial. Clin Cancer Res. 2004;10(14):4639-44. Notes: Q3B? D? N25 BC HT IHC FIS. [pmid: 15269135].
Zidan J, Dashkovsky I, Stayerman C, Basher W, Cozacov C, Hadary A. Comparison of HER-2 overexpression in primary breast cancer and metastatic sites and its effect on biological targeting therapy of metastatic disease. Br J Cancer. 2005;93(5):552-6. Notes: Q1? Q2? PRO N50 BC TRZ IHC FIS (primary tumor vesus mets). [pmid: 16106267].
Zinner RG, Glisson BS, Fossella FV, et al. Trastuzumab in combination with cisplatin and gemcitabine in patients with Her2-overexpressing, untreated, advanced non-small cell lung cancer: report of a phase II trial and findings regarding optimal identification of patients with Her2-overexpressing disease. Lung Cancer. 2004;44(1):99-110. Notes: Q5 PII FEW LC ELS. [pmid: 15013588].