# Appendix A. Exact Search Strings

MEDLINE search (performed through 2/23/07)

EMBASE search (performed through 2/23/07)

Cochrane Controlled Clinical Trials Register (performed through 2/23/07)

Database Search Strategies:

- Genes, erbB-2[MeSH] OR Receptor, erbB-2[MeSH] OR
- “Her-2*”[tiab] OR “Her2*”[tiab] OR “erbB-2”[tiab] OR “erbB2”[tiab] OR
- “epidermal growth factor receptor-2”[tiab] OR
- “epidermal growth factor receptor 2”[tiab] OR
- receptor, epidermal growth factor[mh] OR
- epidermal growth factor receptor-neu receptor[nm])

NOT

- (animals [mh] NOT humans[mh])

For key questions 1 and 2 the results of the above search were combined with the results of a search using:

- Immunohistochemistry[MeSH] OR immunohistochemistry[tiab] OR
- immunocytochemistry[tiab] OR “IHC”[tiab] OR
- In Situ Hybridization, Fluorescence[MeSH] OR
- “fluorescence in situ hybridization”[tiab] OR
- “fluorescence in-situ hybridization”[tiab] OR “FISH”[tiab] OR
- (chromogenic[tiab] AND hybridization[tiab]) OR “CISH”[tiab] OR
- ((gold-facilitated[tiab] OR autometallographic[tiab] OR “bright field”[tiab] OR bright-field[tiab]) AND hybridization[tiab]) OR
- “GOLDFISH”[tiab]

AND

- Breast neoplasms[MeSH] OR “breast neoplasm*”[tiab] OR
- “breast cancer*”[tiab] OR “breast tumor*”[tiab] OR “breast tumour*”[tiab]

For key question 3, the results of the first search above were combined with the results of a search using:

- serum[tiab] OR blood[tiab] OR circulating[tiab]

AND

- Breast neoplasms[MeSH] OR “breast neoplasm*”[tiab] OR
- “breast cancer*”[tiab] OR “breast tumor*”[tiab] OR “breast tumour*”[tiab]

For key question 4, the results of the first search above were combined with the results of a search using:

- “Ovarian Neoplasms”[MeSH] OR
- “Lung Neoplasms”[MeSH] OR
- “Prostatic Neoplasms”[MeSH] OR
- “Colorectal Neoplasms”[MeSH] OR
- “Stomach Neoplasms”[MeSH] OR
- “Esophageal Neoplasms”[MeSH] OR
- “Urinary Bladder Neoplasms”[MeSH] OR
- “Uterine Neoplasms”[MeSH] OR
- “Uterine Cervical Neoplasms”[MeSH] OR
- “Head and Neck Neoplasms”[MeSH] OR
- “Thyroid Neoplasms”[MeSH] OR
- ((neoplasm*[tiab] OR cancer[tiab] OR cancers[tiab] OR tumor[tiab] OR tumors[tiab] OR tumour*[tiab]) NOT breast[ti])

The results of all of the above searches were limited to citations also identified by the Cochrane Handbook search strategy for controlled trials (Alderson et al. 2004):

- randomized controlled trial [pt] OR
- controlled clinical trial [pt] OR
- randomized controlled trials [mh] OR
- random allocation [mh] OR
- double-blind method [mh] OR
- single-blind method [mh] OR
- clinical trial [pt] OR
- clinical trials [mh] OR
- “clinical trial” [tw] OR
- ((singl* [tw] OR doubl* [tw] OR trebl* [tw] OR tripl* [tw]) AND (mask* [tw] OR blind* [tw])) OR
- placebos [mh] OR
- placebo* [tw] OR
- random* [tw] OR
- research design [mh:noexp] OR
- comparative study [mh] OR
- evaluation studies [mh] OR
- follow-up studies [mh] OR
- prospective studies [mh] OR
- control* [tw] OR
- prospectiv* [tw] OR
- volunteer* [tw])