# Appendixes

Appendix A. Search Strategies

Appendix B. Data Assessment, Data Abstraction and Quality Assessment Forms

Appendix C. Evidence Tables

Appendix D. Reference List of Excluded Studies

Appendix E. Additional Acknowledgments

Appendix F. Quality Assessment

Appendix G. Funnel Plots

Appendix H. Instruments Used in the Assessment of Treatment Outcomes

Appendix I. List of Unobtained Articles