# Appendix I. List of Unobtained Articles

## References

Anonymous. Sublingual apomorphine: new preparation. In erectile disorders: a narrow therapeutic margin. Prescrire Int 2002; 11(59):76–79.
De Siati M, Saugo M, Franzolin N. The start of pharmacological activity after sublingual administration of sildenafil citrate in 30 patients affected by erectile dysfunction. Arch Ital Urol Androl. 2003;75(1):18-20. [pmid: 12741340].
Gogtay NJ, Bichile SK, Pinto CJ, et al. Erectile dysfunction and sildenafil citrate.[comment]. J Assoc Physicians India. 2001;49:871-872. [pmid: 11837751].
Guay AT, Perez JB, Velasquez E, et al. Clinical experience with intraurethral alprostadil (MUSE) in the treatment of men with erectile dysfunction. A retrospective study. Medicated urethral system for erection. Eur Urol. 2000;38(6):671-676. [pmid: 11111182].
Tsai YS, Lin JS, Lin YM. Safety and efficacy of alprostadil sterile powder (S. Po., CAVERJECT) in diabetic patients with erectile dysfunction. Eur Urol. 2000;38(2):177-183. [pmid: 10895010].
Cecchi M, Sepich CA, Felipetto R, et al. Vacuum constriction device and topical minoxidil for management of impotence. Arch Esp Urol. 1995;48(10):1058-1059. [pmid: 8588728].
Brooks DP, Giuliano F. Genitourinary diseases. Drug Discovery Today: Therapeutic Strategies 2005; 2(1):iii–iiv.
Anonymous. Erratum: Efficacy and tolerability of sildenafil in Indian males with erectile dysfunction: A double-blind, randomized, placebo controlled, crossover study (Indian Journal of Pharmacology (2004) vol. 37 (5) (317)). Indian Journal of Pharmacology 2004; 36(6):391.
Bayes M, Rabasseda X, Prous JR. Gateways to Clinical Trials. Methods & Findings in Experimental & Clinical Pharmacology 2004; 26(9):723–753.
Martinez-Jabaloyas JM, Gil-Salom M, Villamon-Fort R, et al. Prognostic factors for response to sildenafil in patients with erectile dysfunction. Eur Urol. 2001;40(6):641-647. [pmid: 11805410].
Grover JK, Vats V, Ajeeta. Sildenafil (Viagra(TM)). Medico-Legal Update 1998; 3(1–2):67–78.
Canale D, Giorgi PM, Lencioni R, et al. Long-term intracavernous self-injection with prostaglandin E1 for the treatment of erectile dysfunction. Int J Androl. 1996;19(1):28-32. [pmid: 8698535].
Chiang HS, Kao YH, Sheu MT. Papaverine and prostaglandin E1 gel applications for impotence. Ann Acad Med Singapore. 1995;24(5):767-769. [pmid: 8579329].
Anonymous. Alprostadil for erectile impotence. Drug Ther Bull 1995; 33(8):61–62.
Cara AM, Lopes-Martins RAB, Antunes E, et al. The role of histamine in human penile erection. Br J Urol. 1995;75(2):220-224. [pmid: 7850330].
Shabsigh R. Efficacy of sildenafil citrate (VIAGRA) is not affected by aetiology of erectile dysfunction. Int J Clin Pract. 1999;102(Jun.):19-20.
Padma-Nathan H. Oral sildenafil citrate (VIAGRA) in the treatment of erectile dysfunction: assessment of erections hard enough for sexual intercourse. Int J Clin Pract. 1999;102(Jun.):13-15.
McMahon C. Comparison of erectile responses to differing doses of prostaglandin PGE1 in an attempt to standardise pharmacological diagnosis of impotence. Journal of Assisted Reproduction & Genetics. 1992;9:265A. [pmid: 1525459].
Bartlik BD, Kaplan P, Kaplan HS. Psychostimulants apparently reverse sexual dysfunction secondary to selective serotonin re-uptake inhibitors. J Sex Marital Ther. 1995;21(4):264-271. [pmid: 8789508].
El Malik EMA. Erectile dysfunction: An update of diagnosis and management. Qatar Medical Journal. 2000;9(2):9-17.
Varela SM, Cadarso SC, Garcia R, V, et al. Sildenafil citrate in treatment of 100 patients with erectile dysfunction. Actas Urologicas Espanolas. 2001;25(5):335-340. N. [pmid: 11512257].
Wespes E, Sternon J, Hirsch E, et al. Sildenafil (Viagra(TM)). Revue Medicale de Bruxelles. 1998;19(5):437-441. N. [pmid: 9844484].

Appendixes and Evidence Tables for this report are provided electronically at http://www.ahrq.gov/downloads/pub/evidence/pdf/erectiledys/erecdys.pdf