# Appendix H. Instruments Used in the Assessment of Treatment Outcomes

## International Index of Erectile Function (IIEF)

Individual items of International Index of Erectile Function Questionnaire and response options (US version)^*^:

* All questions are preceded by the phrase “Over the past 4 weeks.”

Q1: How often were you able to get an erection during sexual activity?

0 = No sexual activity

1 = Almost never/never

2 = A few times (much less than half the time)

3 = Sometimes (about half the time)

4 = Most times (much more than half the time)

5 = Almost always/always

Q2: When you had erections with sexual stimulation, how often were your erections hard enough for penetration?

0 = No sexual activity

1 = Almost never/never

2 = A few times (much less than half the time)

3 = Sometimes (about half the time)

4 = Most times (much more than half the time)

5 = Almost always/always

Q3: When you attempted sexual intercourse, how often were you able to penetrate (enter) your partner?

0 = Did not attempt intercourse

I = Almost never/never

2 = A few times (much less than half the time)

3 = Sometimes (about half the time)

4 = Most times (much more than half the time)

5 = Almost always/always

Q4: During sexual intercourse, how often were you able to maintain your erection after you had penetrated (entered) your partner?

0 = Did not attempt intercourse

I = Almost never/never

2 = A few times (much less than half the time)

3 = Sometimes (about half the time)

4 = Most times (much more than half the time)

5 = Almost always/always

Q5: During sexual intercourse, how difficult was it to maintain your erection to completion of intercourse?

0 = Did not attempt intercourse

1 = Extremely difficult

2 = Very difficult

3 = Difficult

4 = Slightly difficult

5 = Not difficult

Q6: How many times have you attempted sexual intercourse?

0 = No attempts

1 = One to two attempts

2 = Three to four attempts

3 = Five to six attempts

4 = Seven to ten attempts

5 = Eleven+ attempts

Q7: When you attempted sexual intercourse, how often was it satisfactory for you?

0 = Did not attempt intercourse

1 = Almost never/never

2 = A few times (much less than half the time)

3 = Sometimes (about half the time)

4 = Most times (much more than half the time)

5 = Almost always/always

Q8: How much have you enjoyed sexual intercourse?

0 = No intercourse

1 = No enjoyment

2 = Not very enjoyable

3 = Fairly enjoyable

4 = Highly enjoyable

5 = Very highly enjoyable

Q9: When you had sexual stimulation or intercourse, how often did you ejaculate?

0 = No sexual stimulation/intercourse

1 = Almost never/never

2 = A few times (much less than half the time)

3 = Sometimes (about half the time)

4 = Most times (much more than half the time)

5 = Almost always/always

Q10: When you had sexual stimulation or intercourse, how often did you have tile feeling of orgasm or climax?

0 = No sexual stimulation/intercourse

1 = Almost never/never

2 = A few times (much less than half the time)

3 = Sometimes (about half the time)

4 = Most times (much more than half the time)

5 = Almost always/always

Q11: How often have you felt sexual desire?

1 = Almost never/never

2 = A few times (much less than half the time)

3 = Sometimes (about half the time)

4 = Most times (much more than half the time)

5 = Almost always/always

Q12: How would you rate your level of sexual desire?

1 = Very low/none at all

2 = Low

3 = Moderate

4 = High

5 = Very high

Q13: How satisfied have you been with your overall sex life?

1 = Very dissatisfied

2 = Moderately dissatisfied

3 = About equally satisfied and dissatisfied

4 = Moderately satisfied

5 = Very satisfied

Q14: How satisfied have you been with your sexual relationship with your partner?

1 = Very dissatisfied

2 = Moderately dissatisfied

3 = About equally satisfied and dissatisfied

4 = Moderately satisfied

5 = Very satisfied

Q15: How do you rate your confidence that you could get and keep an erection?

1 = Very low

2 = Low

3 = Moderate

4 = High

5 = Very high

## IIEF domains and the scoring

Domain | Items | Score Range | Minimum Score | Maximum Score
Erectile Function | 1,2, 3, 4, 5, 15 | 0 (or 1)–5 | 1 | 30
Orgasmic Function | 9, 10 | 0–5 | 0 | 10
Sexual Desire | 11, 12 | 1–5 | 2 | 10
Intercourse Satisfaction | 6, 7, 8 | 0–5 | 0 | 15
Overall Satisfaction | 13, 14 | 1–5 | 2 | 10

## IIEF-5 scoring system

Question | Score
Over the past six months: | 1 | 2 | 3 | 4 | 5
How do you rate your confidence that you could get and keep an erection? | Very low | Low | Moderate | High | Very high
When you had erections with sexual stimulation, how often were your erections hard enough for penetration? | Almost never or never | Much less than half the time | About half the time | Much more than half the time | Almost always or always
During sexual intercourse, how often were you able to maintain your erection after you had penetrated (entered) your partner? | Almost never or never | Much less than half the time | About half the time | Much more than half the time | Almost always or always
During sexual intercourse how difficult was it to maintain your erection to the completion of intercourse? | Extremely difficult | Very difficult | Difficult | Slightly difficult | Not difficult
When you attempted sexual intercourse, how often was it satisfactory for you? | Almost never or never | Much less than half the time | About half the time | Much more than half the time | Almost always or always
The IIEF-5 score is the sum of questions 1 to 5. The lowest score is 5 and the highest score 25.

## Sexual Encounter Profile (SEP- Questions 2 and 3)

SEP-Q2: Were you able to insert your penis into your partner's vagina?

SEP-Q3: Did your erection last long enough for you to have successful intercourse?

## Global Assessment Question (GAQ)

GAQ-Q1: Has the treatment you have been taking improved your erectile function?

GAQ-Q2: If yes, has the treatment improved your ability to engage in sexual activity?