# Appendix G. Funnel Plots

## Sildenafil

### Figure G-1. Sildenafil (any dose) vs. Placebo: mean IIEF-Q3 score

[image]

### Figure G-2. Sildenafil (any dose) vs. Placebo: mean IIEF-Q4 score

[image]

### Figure G-3. Sildenafil (any dose) vs. Placebo: participants with improved erection (GEQ-Q1)

[image]

### Figure G-4. Sildenafil (any dose) vs. Placebo: mean IIEF-Q3 score Participants with type I-II diabetes

[image]

### Figure G-5. Sildenafil (any dose) vs. Placebo: mean IIEF-Q4 score Participants with type I-II diabetes

[image]

### Figure G-6. Sildenafil (any dose) vs. Placebo: patients with improved erection (GEQ-Q1) Participants with type I-II diabetes

[image]

### Figure G-7. Sildenafil (any dose) vs. Placebo: participants with improved erection (GEQ-Q1) Participants with type II diabetes

[image]

### Figure G-8. Sildenafil (25 mg) vs. Sildenafil (50 mg): participants with improved erection (GEQ-Q1)

[image]

## Vardenafil

### Any dose vs. Placebo

### Figure G-9. Vardenafil (any dose) vs. Placebo: mean IIEF ‘EF domain’ score at week 12

[image]

### Figure G-10. Vardenafil (any dose) vs. Placebo: patients with mean IIEF ‘EF domain’ score ≥ 26

[image]

### Figure G-11. Vardenafil (any dose) vs. Placebo: patients with improved erection (GAQ-Q1)

[image]

## Tadalfil

### 20 mg vs. Placebo

### Figure G-12. Tadalafil (20 mg) vs. Placebo: mean IIEF-‘EF domain’ score change

[image]

### Figure G-13. Tadalafil (20 mg) vs. Placebo: % mean SEP-Q2 score change

[image]

### Figure G-14. Tadalafil (20 mg) vs. Placebo: patients with improved erection (GAQ-Q1)

[image]

### 20 mg vs. 10 mg

### Figure G-15. Tadalafil (20mg) vs. Tadalafil (10mg): mean IIEF ‘EF domain’ score

[image]

### Figure G-16. Tadalafil (20mg) vs. Tadalafil (10mg): % mean SEP-Q2 score change

[image]