# Appendix F. Quality Assessment

## Randomized Controlled Trials (RCTs)

Table F-1 Quality Assesment of RCTs

Author Year | Jadad Q-1 | Jadad Q-2 | Jadad Q-3 | Jadad Q-4 | Jadad Q-5 | Total Scores | Allocation Concealment
Palmer 2000^1^ | 1 | 0 | 0 | 1 | 0 | 2 | Unclear
Seidman 2001^2^ | 1 | 0 | 1 | 1 | 1 | 4 | Unclear
Kongkanand 2003^3^ | 1 | 0 | 1 | 1 | 1 | 4 | Unclear
Stuckey 2003^4^ | 1 | 1 | 1 | 1 | 1 | 5 | Adequate
Choi 2003^5^ | 1 | 0 | 1 | 1 | 1 | 4 | Unclear
Levinson 2003^6^ | 1 | 0 | 1 | 0 | 1 | 3 | Unclear
DeBusk 2004^7^ | 1 | 1 | 1 | 0 | 1 | 4 | Unclear
Boolell 1996^8^ | 1 | 0 | 1 | 0 | 1 | 3 | Unclear
Goldstein 1998^9^ | 1 | 0 | 1 | 1 | 1 | 4 | Unclear
Tan 2000^10^ | 1 | 0 | 1 | 1 | 1 | 4 | Unclear
Meuleman 2001^11^ | 1 | 0 | 1 | 1 | 1 | 4 | Unclear
Eardley 2001^12^ | 1 | -1 | 1 | 1 | 0 | 2 | Unclear
Young 2002^13^ | 1 | 0 | 1 | 1 | 0 | 3 | Unclear
von Keitz 2002^14^ | 1 | -1 | 1 | 0 | 1 | 2 | Unclear
Goldstein 2003^15^ | 1 | 0 | 1 | 0 | 1 | 3 | Unclear
Nurnberg 2003^16^ | 1 | 1 | 1 | 1 | 1 | 5 | Adequate
Incrocci 2003^17^ | 1 | 0 | 1 | 0 | 1 | 3 | Unclear
Hellstrom 2003^18^ | 1 | 1 | 1 | 0 | 1 | 4 | Adequate
Price 1998^19^ | 1 | 0 | 1 | 0 | 1 | 3 | Unclear
Rendell 1999^20^ | 1 | 1 | 1 | 1 | 1 | 5 | Adequate
Christiansen 2000^21^ | 1 | 1 | 1 | 1 | 1 | 5 | Adequate
Olsson 2000^22^ | 1 | 0 | 1 | 0 | 1 | 3 | Unclear
Chen 2001^23^ | 1 | 0 | 1 | 1 | 1 | 4 | Unclear
Boulton 2001^24^ | 1 | 0 | 1 | 1 | 0 | 3 | Unclear
Hussain 2001^25^ | 1 | 0 | 1 | 0 | 0 | | Unclear
Lewis 2001^26^ | 1 | 0 | 1 | 0 | 0 | 2 | Unclear
Brock 2002^27^ | 1 | 0 | 0 | 0 | 1 | 2 | Unclear
Porst 2003^28^ | 1 | 0 | 1 | 0 | 0 | 2 | Unclear
Montorsi 2004^29^ | 1 | 0 | 1 | 0 | 1 | 2 | Unclear
Safarinejad 2004^30^ | 1 | 1 | 1 | 0 | 1 | 4 | Adequate
Webster 2004^31^ | 1 | -1 | 1 | 0 | 1 | 2 | Unclear
Giuliano 2005^32^ | 1 | -1 | 1 | 0 | 0 | 1 | Unclear
Hatzichristou 2005^33^ | 1 | -1 | 1 | 0 | 0 | 2 | Unclear
Eardley 2005^34^ | 1 | 0 | 0 | 0 | 1 | 2 | Unclear
Cavallini 2005^35^ | 1 | -1 | 1 | 1 | 1 | 3 | Unclear
Diamond 2005^36^ | 1 | 0 | 1 | 0 | 1 | 3 | Unclear
Hellstrom 2005^37^ | 1 | 0 | 1 | 0 | 0 | 2 | Unclear
Melman 2005^38^ | 0 | 0 | 0 | 0 | 0 | 0 | Unclear
Valiquette 2005^39^ | 1 | 0 | 1 | 0 | 1 | 3 | Unclear
Shabsigh 2005^40^ | 1 | 0 | 1 | 0 | 0 | 2 | Unclear
Ardicoglu 2005^41^ | 0 | 0 | 0 | 0 | 0 | 0 | Unclear
Melnik 2005^42^ | 1 | 1 | 0 | 0 | 1 | 3 | Adequate
Seyam 2005^43^ | 1 | 0 | 0 | 0 | 1 | 2 | Unclear
Mirone 2005^44^ | 1 | 0 | 0 | 0 | 1 | 2 | Unclear
Nehra 2005^45^ | 1 | 1 | 1 | 0 | 1 | 4 | Unclear
Young 2005^46^ | 1 | -1 | 1 | 0 | 0 | 1 | Unclear
McMahon 2005^47^ | 1 | 1 | 1 | 1 | 1 | 5 | Unclear
Fowler 2005^48^ | 1 | 1 | 1 | 1 | 0 | 4 | Adequate
Haren 2005^49^ | 1 | 1 | 1 | 1 | 0 | 4 | Unclear
Carson 2005^50^ | 1 | 0 | 1 | 0 | 1 | 3 | Unclear
Mahon 2005^51^ | 1 | 0 | 1 | 1 | 0 | 3 | Unclear
Rosano 2005^52^ | 1 | 0 | 1 | 1 | 1 | 4 | Unclear
Kirby 2005^53^ | 1 | 0 | 1 | 1 | 1 | 4 | Unclear
De Rose 2005^54^ | 1 | 1 | 0 | 0 | 1 | 3 | Adequate
Gontero 2005^55^ | 1 | 1 | 1 | 1 | 1 | 5 | Adequate
Katz 2005^56^ | 1 | 1 | 1 | 0 | 1 | 4 | Unclear
Carson 2004^50^ | 1 | -1 | 1 | 1 | 1 | 4 | Unclear
Fonseca 2004^57^ | 1 | 0 | 1 | 0 | 0 | 2 | Unclear
Wheatley 2004^58^ | 1 | 1 | 1 | 1 | 0 | 4 | Adequate
Abdel-Naser 2004^59^ | 1 | 0 | 0 | 0 | 1 | 2 | Unclear
Parsons 2004^60^ | 1 | 1 | 1 | 0 | 0 | 3 | Inadequate
Deveci 2004^61^ | 1 | 0 | 1 | 0 | 0 | 2 | Unclear
Seftel 2004^62^ | 1 | 0 | 0 | 0 | 0 | 1 | Inadequate
Eardley 2004^63^ | 1 | 0 | 0 | 0 | 0 | 1 | Unclear
Gentile 2004^64^ | 1 | -1 | 1 | 0 | 0 | 2 | Unclear
Staab 2004^65^ | 1 | -1 | 1 | 1 | 1 | 3 | Adequate
Montorsi 2004^66^ | 1 | 0 | 1 | 1 | 0 | 3 | Unclear
Skoumal 2004^67^ | 1 | 1 | 1 | 1 | 1 | 5 | Unclear
Rosen 2004^68^ | 1 | -1 | 1 | 0 | 1 | 2 | Unclear
Shabsigh 2004^69^ | 1 | 0 | 1 | 1 | 0 | 3 | Unclear
Seftel 2004^70^ | 1 | 1 | 1 | 1 | 1 | 5 | Unclear
Nagao 2004^71^ | 1 | -1 | 1 | 1 | 1 | 3 | Adequate
Perimenis 2004^72^ | 1 | -1 | 1 | -1 | 1 | 1 | Unclear
Tignol 2004^73^ | 1 | 0 | 0 | 0 | 0 | 1 | Unclear
Perimenis 2004^74^ | 1 | 1 | 1 | 1 | 1 | 5 | Unclear
Carson 2004^75^ | 1 | 1 | 0 | 0 | 1 | 3 | Unclear
Eardley 2004^76^ | 1 | 0 | 1 | 0 | 1 | 3 | Unclear
Stief 2004^77^ | 1 | 1 | 0 | 0 | 0 | 2 | Unclear
Hatzichristou 2004^78^ | 1 | 0 | 1 | 1 | 1 | 4 | Unclear
Cavallini 2004^79^ | 1 | 1 | 1 | 1 | 1 | 5 | Adequate
Rosen 2004^80^ | 1 | 1 | 0 | 0 | 0 | 2 | Adequate
von Keitz 2004^81^ | 1 | 0 | 1 | 1 | 0 | 3 | Unclear
Leder 2004^82^ | 1 | 0 | 1 | 1 | 1 | 4 | Unclear
Diamond 2004^83^ | 1 | 1 | 1 | 0 | 0 | 3 | Unclear
Mancini 2004^84^ | 1 | 0 | 1 | 1 | 0 | 3 | Unclear
Perimenis 2004^85^ | 1 | 0 | 1 | 0 | 1 | 3 | Unclear
Govier 2003^86^ | 1 | -1 | 0 | 0 | 0 | 1 | Unclear
Fox 2003^87^ | 1 | 0 | 0 | 0 | 1 | 2 | Unclear
Brock 2003^88^ | 1 | -1 | 1 | 0 | 1 | 2 | Unclear
Padma-Nathan 2003^89^ | 1 | 0 | 1 | 1 | 0 | 3 | Unclear
Hellstrom 2003^90^ | 1 | 1 | 1 | 1 | 1 | 5 | Adequate
Montorsi 2003^91^ | 1 | 0 | 1 | 1 | 1 | 4 | Unclear
Porst 2003^92^ | 1 | -1 | 0 | 0 | 1 | 1 | Unclear
Boyanov 2003^93^ | 1 | 0 | 1 | 0 | 0 | 2 | Unclear
Anderson 2003^94^ | 1 | 1 | 1 | 1 | 1 | 5 | Unclear
Steidle 2003^95^ | 1 | 0 | 0 | 0 | 1 | 2 | Unclear
Gontero 2003^96^ | 1 | 1 | 0 | 0 | 1 | 3 | Unclear
Aversa 2003^97^ | 1 | -1 | 0 | 0 | 0 | 0 | Unclear
Hagemann 2003^98^ | 1 | 0 | 0 | 0 | 0 | 1 | Unclear
Montorsi 2003^99^ | 1 | 0 | 0 | 0 | 0 | 1 | Unclear
McNicholas 2003^100^ | 1 | 0 | 0 | 0 | 0 | 1 | Unclear
Padma-Nathan 2003^101^ | 1 | 0 | 1 | 0 | 0 | 2 | Unclear
Harding 2002^102^ | 1 | -1 | 1 | 0 | 0 | 2 | Unclear
Steidle 2002^103^ | 1 | 0 | 1 | 0 | 0 | 2 | Unclear
Thadani 2002^104^ | 1 | 0 | 1 | 0 | 1 | 3 | Unclear
Saenz, I 2002^105^ | 1 | 1 | 1 | 0 | 0 | 3 | Inadequate
Hellstrom 2002^106^ | 1 | 0 | 1 | 0 | 1 | 3 | Unclear
Seibel 2002^107^ | 1 | 0 | 1 | 0 | 1 | 3 | Unclear
Bocchi 2002^108^ | 1 | 0 | 1 | 0 | 1 | 3 | Unclear
Ugarte 2002^109^ | 1 | 1 | 1 | 0 | 1 | 4 | Adequate
Gomez 2002^110^ | 1 | 1 | 1 | 1 | 1 | 5 | Adequate
Becher 2002^111^ | 1 | 0 | 1 | 0 | 1 | 3 | Unclear
Glina 2002^112^ | 1 | 0 | 0 | 0 | 0 | 1 | Unclear
Schanz 2002^113^ | 1 | 0 | 1 | 1 | 1 | 4 | Unclear
Padma-Nathan 2002^114^ | 1 | 0 | 1 | 0 | 1 | 3 | Unclear
Lebret 2002^115^ | 1 | 0 | 1 | 1 | 0 | 3 | Unclear
Lindsey 2002^116^ | 0 | 0 | 0 | 0 | 0 | 0 | Unclear
Lim 2002^117^ | 0 | 0 | 0 | 0 | 1 | 1 | Unclear
van der Windt 2002^118^ | 1 | 1 | 1 | 0 | 0 | 3 | Unclear
Kunelius 2002^119^ | 1 | 1 | 1 | 1 | 1 | 5 | Unclear
Lammers 2002^120^ | 1 | 0 | 1 | 1 | 1 | 4 | Unclear
De Rose 2002^121^ | 1 | 0 | 0 | 0 | 1 | 2 | Unclear
Eardley 2002^122^ | 1 | 1 | 1 | 1 | 1 | 5 | Inadequate
Hatzichristou 2001^123^ | 1 | 0 | 1 | 0 | 0 | 2 | Unclear
Incrocci 2001^124^ | 1 | 1 | 0 | 0 | 1 | 3 | Adequate
Stark 2001^125^ | 1 | 0 | 1 | 1 | 1 | 4 | Unclear
Choppin 2001^126^ | 0 | 0 | 1 | 1 | 1 | 3 | Unclear
Porst 2001^127^ | 1 | 0 | 1 | 0 | 1 | 3 | Unclear
Mann 2001^128^ | 1 | 0 | 1 | 0 | 0 | 2 | Unclear
Dula 2001^129^ | 1 | 0 | 0 | 0 | 0 | 1 | Unclear
Safarinejad 2001^130^ | 1 | 0 | 1 | 1 | 1 | 4 | Unclear
Gomaa 2001^131^ | 1 | 0 | 1 | 0 | 1 | 3 | Unclear
Olsson 2001^132^ | 1 | 0 | 1 | 0 | 0 | 2 | Unclear
Padma-Nathan 2001^133^ | 1 | 0 | 1 | 0 | 0 | 2 | Unclear
Klotz 2001^134^ | 1 | 0 | 1 | 1 | 0 | 3 | Adequate
Goldstein 2001^135^ | 1 | 0 | 1 | 0 | 0 | 2 | Unclear
Kloner 2001^136^ | 1 | 0 | 1 | 0 | 0 | 2 | Unclear
Fu 2000^137^ | 1 | 0 | 1 | 0 | 0 | 2 | Unclear
Montorsi 2000^138^ | 1 | -1 | 1 | 1 | 1 | 3 | Unclear
Enzlin 2000^139^ | 1 | 0 | 1 | 0 | 0 | 2 | Unclear
Baum 2000^140^ | 1 | 0 | 0 | 0 | 0 | 1 | Unclear
Wessells 2000^141^ | 1 | 0 | 1 | 1 | 1 | 4 | Unclear
Cappelleri 2000^142^ | 1 | 0 | 1 | 0 | 1 | 3 | Unclear
Ekman 2000^143^ | 1 | 0 | 0 | 0 | 0 | 1 | Unclear
Dula 2000 ^144^ | 1 | 0 | 1 | 0 | 1 | 3 | Unclear
Rabkin 2000^145^ | 1 | 0 | 1 | 0 | 0 | 2 | Unclear
Shabsigh 2000^146^ | 1 | 0 | 0 | 0 | 0 | 1 | Unclear
Anderson 1999^147^ | 1 | 0 | 1 | 1 | 1 | 4 | Unclear
Palmer 1999^148^ | 1 | 1 | 1 | 1 | 1 | 5 | Adequate
Shokeir 1999^149^ | 1 | 1 | 0 | 0 | 0 | 2 | Unclear
Le Roux 1999^150^ | 1 | 0 | 0 | 0 | 1 | 2 | Unclear
Sandhu 1999^151^ | 1 | 0 | 1 | 1 | 1 | 4 | Unclear
Costabile 1999^152^ | 1 | 0 | 0 | 0 | 1 | 2 | Unclear
Dinsmore 1999^153^ | 1 | 0 | 1 | 1 | 1 | 4 | Adequate
Chen 1999^154^ | 1 | 0 | 1 | 0 | 0 | 2 | Unclear
Montorsi 1999^155^ | 1 | 1 | 1 | 0 | 0 | 3 | Unclear
Dinsmore 1999^156^ | 1 | 0 | 1 | 0 | 0 | 2 | Unclear
Gramkow 1999^157^ | 1 | 0 | 1 | 0 | 1 | 3 | Unclear
Klotz 1999^158^ | 1 | 0 | 1 | 1 | 1 | 4 | Unclear
Eardley 1999^159^ | 1 | 0 | 1 | 1 | 0 | 3 | Unclear
Hartmann 1999^160^ | 1 | 0 | 1 | 0 | 0 | 2 | Unclear
Feldman 1999^161^ | 1 | -1 | 0 | 0 | 0 | 1 | Unclear
Young 1999^162^ | 1 | 0 | 1 | 0 | 0 | 2 | Unclear
Padma-Nathan 1998^163^ | 1 | 0 | 1 | 0 | 1 | 3 | Unclear
Williams 1998^164^ | 1 | 0 | 1 | 0 | 0 | 2 | Unclear
Foldvari 1998^165^ | 1 | 0 | 1 | 0 | 0 | 2 | Unclear
Costabile 1998^166^ | 1 | 0 | 1 | 1 | 1 | 4 | Unclear
Williams 1998^167^ | 1 | -1 | 1 | 0 | 0 | 1 | Unclear
Engel 1998^168^ | 1 | 0 | 1 | 1 | 0 | 3 | Unclear
Peterson 1998^169^ | 1 | 0 | 1 | 0 | 0 | 2 | Unclear
Becker 1998^170^ | 1 | -1 | 1 | 0 | 0 | 2 | Unclear
Buvat 1998^171^ | 1 | 0 | 1 | 0 | 0 | 2 | Unclear
Montorsi 1998^172^ | 1 | 0 | 1 | 0 | 0 | 2 | Unclear
Sogari 1997^173^ | 1 | 0 | 1 | 0 | 1 | 3 | Unclear
Meinhardt 1997^174^ | 1 | 0 | 1 | 1 | 1 | 4 | Unclear
Vogt 1997^175^ | 1 | 0 | 0 | 0 | 0 | 1 | Unclear
Montorsi 1997^176^ | 1 | 0 | 0 | 0 | 0 | 1 | Unclear
Soderdahl 1997^177^ | 1 | 0 | 1 | 1 | 1 | 4 | Unclear
Schiavi 1997^178^ | 1 | 0 | 1 | 0 | 1 | 3 | Unclear
Bechara 1997^179^ | 1 | 0 | 0 | 0 | 0 | 1 | Unclear
Kunelius 1997^180^ | 1 | -1 | 0 | 0 | 0 | 0 | Unclear
Rowland 1997^181^ | 1 | 0 | 1 | 0 | 0 | 2 | Unclear
Padma-Nathan 1997^182^ | 1 | 0 | 1 | 0 | 1 | 3 | Unclear
Aversa 1996^183^ | 1 | 0 | 1 | 0 | 0 | 2 | Unclear
Hellstrom 1996^184^ | 0 | 0 | 1 | 1 | 0 | 2 | Adequate
Colli 1996^185^ | 1 | 0 | 1 | 0 | 1 | 3 | Unclear
Godschalk 1996^186^ | 1 | 0 | 0 | 0 | 0 | 1 | Unclear
Mann 1996^187^ | 1 | 0 | 1 | 0 | 0 | 2 | Unclear
Gheorghiu 1996^188^ | 1 | 0 | 1 | 0 | 0 | 3 | Unclear
Peskircioglu 1996^189^ | 1 | 1 | 1 | 0 | 1 | 4 | Unclear
Gomaa 1996^190^ | 1 | 0 | 1 | 0 | 1 | 3 | Unclear
Linet 1996^191^ | 1 | 0 | 1 | 0 | 0 | 2 | Unclear
Bechara 1996^192^ | 1 | 0 | 0 | 0 | 0 | 1 | Unclear
Knoll 1996^193^ | 1 | 0 | 1 | 0 | 0 | 2 | Unclear
Wegner 1995^194^ | 1 | 0 | 1 | 1 | 1 | 4 | Unclear
van Ahlen 1995^195^ | 1 | 0 | 0 | 0 | 0 | 1 | Unclear
Guay 1995^196^ | 1 | 0 | 0 | 0 | 0 | 1 | Unclear
Vanderschueren 1995^197^ | 1 | 1 | 1 | 1 | 0 | 4 | Unclear
Georgitis 1995^198^ | 1 | 0 | 1 | 0 | 1 | 3 | Unclear
el-Saleh 1995^199^ | 1 | 1 | 1 | 1 | 0 | 4 | Unclear
Ogrinc 1995^200^ | 1 | 0 | 1 | 0 | 0 | 2 | Unclear
Kattan 1995^201^ | 1 | 0 | 1 | 0 | 0 | 2 | Unclear
Martinez-Pineiro 1995^202^ | 1 | 1 | 0 | 0 | 0 | 2 | Unclear
Cavallini 1994^203^ | 1 | 0 | 1 | 0 | 0 | 2 | Unclear
Lazzeri 1994^204^ | 1 | 0 | 1 | 1 | 1 | 4 | Unclear
Wegner 1994^205^ | 1 | 0 | 0 | 0 | 0 | 1 | Unclear
Montorsi 1994^206^ | 1 | 1 | 1 | 0 | 0 | 3 | Unclear
Schramek 1994^207^ | 1 | 0 | 0 | 0 | 0 | 1 | Unclear
Kurt 1994^208^ | 1 | -1 | 0 | 0 | 0 | 1 | Unclear
Godschalk 1994^209^ | 1 | 0 | 1 | 1 | 1 | 4 | Adequate
Brennemann 1993^210^ | 1 | 0 | 1 | 1 | 0 | 3 | Unclear
von Heyden 1993^211^ | 1 | 0 | 1 | 0 | 1 | 3 | Unclear
Moriel 1993^212^ | 1 | 0 | 1 | 0 | 1 | 3 | Unclear
Porst 1993^213^ | 1 | -1 | 1 | 1 | 1 | 3 | Unclear
Korenman 1993^214^ | 1 | 0 | 0 | 0 | 0 | 1 | Unclear
Costa 1993^215^ | 1 | 0 | 1 | 1 | 0 | 3 | Unclear
Allen 1992^216^ | 1 | 0 | 0 | 0 | 0 | 1 | Unclear
Mahmoud 1992^217^ | 1 | 0 | 1 | 0 | 0 | 2 | Unclear
Cavallini 1991^218^ | 1 | 1 | 1 | 0 | 1 | 4 | Unclear
Kattan 1991^219^ | 1 | 1 | 1 | -1 | 0 | 2 | Unclear
Segraves 1991^220^ | 1 | 0 | 1 | 0 | 0 | 2 | Unclear
Floth 1991^221^ | 1 | 1 | 1 | 0 | 0 | 3 | Unclear
Sonda 1990^222^ | 1 | 0 | 1 | 1 | 0 | 3 | Unclear
Roy 1990^223^ | 1 | 0 | 1 | 1 | 0 | 3 | Unclear
Earle 1990^224^ | 1 | 0 | 0 | 0 | 0 | 1 | Unclear
van Ahlen 2005^225^ | 0 | 0 | 1 | 1 | 1 | 3 | Unclear
Goldstein 2005^226^ | 1 | 0 | 1 | 0 | 1 | 3 | Unclear
Fisher 2005^227^ | 1 | -1 | 0 | 0 | 0 | 0 | Unclear
Carrier 2005^228^ | 1 | 0 | 1 | 1 | 1 | 4 | Unclear
Moncada 2005^229^ | 1 | 1 | 1 | 1 | 1 | 5 | Unclear
Hatzichristou 2005^230^ | 1 | 1 | 1 | 1 | 1 | 5 | Unclear
Patterson 2005^231^ | 1 | -1 | 1 | 1 | 1 | 3 | Unclear
Albuquerque 2005^232^ | 1 | 0 | 0 | 0 | 0 | 1 | Unclear
Yonessi 2005^233^ | 1 | 0 | 1 | 0 | 1 | 3 | Unclear
Shamloul 2005^234^ | 1 | 0 | 1 | 1 | 1 | 4 | Unclear
McMahon 2005^235^ | 1 | 1 | 1 | 1 | 1 | 5 | Unclear
Speel 2005^236^ | 1 | 1 | 1 | 0 | 0 | 3 | Unclear
Chen 2004^237^ | 1 | 0 | 0 | 0 | 0 | 1 | Unclear
Rosen 2004^238^ | 1 | 1 | 0 | 0 | 1 | 3 | Unclear
Donatucci 2004^239^ | 1 | 0 | 0 | 0 | 1 | 2 | Unclear
Gingell 2004^240^ | 1 | 1 | 1 | 0 | 1 | 4 | Unclear
Montorsi 2004^241^ | 1 | -1 | 1 | 0 | 1 | 3 | Unclear
Pickering 2004^242^ | 1 | -1 | 1 | 0 | 0 | 2 | Unclear
Pavone 2004^243^ | 1 | 0 | 1 | -1 | 1 | 3 | Unclear
Bawa 2004^244^ | 1 | -1 | 1 | 1 | 1 | 3 | Unclear
Petrov 2003^245^ | 1 | 0 | 1 | 0 | 1 | 3 | Unclear
Dunzendorfer 2002^246^ | 1 | 0 | 0 | 0 | 1 | 2 | Unclear
Glina 2001^247^ | 1 | 0 | 1 | 0 | 0 | 2 | Unclear
Giammusso 1996^248^ | 1 | 0 | 0 | 0 | 1 | 2 | Unclear
Garceau 1996^249^ | 1 | 0 | 0 | 0 | 0 | 1 | Unclear
Claes 1992^250^ | 1 | 0 | 1 | 1 | 1 | 4 | Unclear
Valiquette 2005^251^ | 1 | 0 | 1 | 0 | 0 | 2 | Unclear
Reiter 1999^252^ | 1 | 0 | 1 | 0 | 0 | 2 | Unclear
Kunelius 1998^253^ | 1 | 0 | 1 | 0 | 0 | 2 | Unclear
Haslam 1992^254^ | 1 | 1 | 1 | 0 | 0 | 3 | Unclear
Rosen 2006^255^ | 1 | 1 | 0 | 0 | 1 | 4 | Unclear
Korenman 1994^256^ | 1 | -1 | 1 | 0 | 0 | 1 | Unclear
Clopper 1993^257^ | 1 | 0 | 1 | 1 | 1 | 4 | Unclear
Wang 2000^258^ | 1 | 0 | 1 | 1 | 0 | 3 | Unclear
Nickel 2007^259^ | 1 | 0 | 1 | 1 | 0 | 3 | Unclear
Yassin 2006^260^ | 1 | 0 | 0 | 0 | 0 | 1 | Unclear
Martin-Morales 2007^261^ | 1 | 0 | 1 | 0 | 1 | 3 | Unclear
Heiman 2007^262^ | 1 | 0 | 1 | 1 | 0 | 2 | Unclear
Bank 2006^263^ | 1 | 0 | 0 | 0 | 1 | 2 | Unclear
McVary 2007^264^ | 1 | 0 | 1 | 0 | 0 | 2 | Unclear
Saylan 2006^265^ | 1 | 1 | 1 | 0 | 1 | 4 | Inadequate
Zinner 2007^266^ | 1 | 0 | 1 | 1 | 0 | 3 | Unclear
Edwards 2006^267^ | 1 | 0 | 1 | 0 | 1 | 3 | Unclear
Rajfer 2007^268^ | 1 | 0 | 1 | 0 | 1 | 3 | Unclear
Valiquette 2006^269^ | 1 | 0 | 1 | 0 | 0 | 2 | Unclear
Wespes 2007^270^ | 1 | 0 | 1 | 0 | 1 | 3 | Unclear
Porst 2006^271^ | 1 | 0 | 1 | 0 | 1 | 3 | Unclear
Yip 2006^272^ | 1 | 0 | 1 | 1 | 0 | 3 | Unclear
Safarinejad 2006^273^ | 1 | 0 | 0 | 0 | 0 | 1 | Unclear
Agostini 2006^274^ | 1 | 0 | 1 | 0 | 1 | 3 | Unclear
Mazo 2006^275^ | 1 | 0 | 1 | 0 | 1 | 3 | Unclear
El-Shafey 2006^276^
Tolra 2006^277^ | 1 | 0 | 1 | 1 | 0 | 3 | Unclear
Ziegler 2006^278^ | 1 | 0 | 1 | 0 | 0 | 2 | Unclear
Ishii 2006^279^ | 1 | 0 | 1 | 0 | 0 | 2 | Unclear
Guo 2006^280^ | 1 | 0 | 0 | 0 | 1 | 2 | Unclear
Nagao 2006^281^ | 1 | 0 | 1 | 1 | 1 | 4 | Unclear
Padma-Nathan 2006^282^ | 1 | 0 | 1 | 1 | 1 | 4 | Unclear
Dean 2006^283^ | 1 | 0 | 1 | 0 | 1 | 3 | Unclear
Seidman 2006^284^ | 1 | 0 | 1 | 0 | 1 | 3 | Unclear
Demir 2006^285^ | 1 | 1 | 1 | 0 | 0 | 3 | Unclear
Althof 2006^286^ | 1 | 0 | 0 | 0 | 0 | 1 | Unclear
Buvat 2006^287^ | 1 | 0 | 0 | 0 | 1 | 2 | Unclear
McMahon 2006^288^ | 1 | 0 | 0 | 0 | 0 | 1 | Unclear
Fava 2006^289^ | 1 | 0 | 1 | 0 | 1 | 3 | Unclear
Gopalakrishnan 2006^290^ | 1 | 0 | 0 | 0 | 0 | 1 | Unclear
Herrmann 2006^291^ | 1 | 1 | 1 | 0 | 1 | 4 | Unclear
Titta 2006^292^ | 1 | 1 | 1 | 0 | 1 | 4 | Unclear
Sommer 2006^293^ | 1 | 1 | 1 | 1 | 1 | 5 | Inadequate
Rochira 2006^294^ | 1 | 0 | 1 | 1 | 0 | 3 | Unclear
O'Leary 2006^295^ | 1 | 0 | 0 | 0 | 0 | 1 | Unclear
Viswaroop 2005^296^ | 1 | 0 | 1 | 0 | 0 | 2 | Unclear
Carson 2005^297^ | 1 | 0 | 0 | 0 | 0 | 1 | Unclear
Kaplan 2007^298^ | 1 | 1 | 1 | 0 | 0 | 3 | Unclear
Choi 2006^299^ | 1 | 1 | 0 | 0 | 0 | 2 | Unclear
Gomaa 2006^300^ | 1 | 0 | 1 | 0 | 0 | 2 | Unclear

## Quality Assessment of Observational Studies

Table F-2 Quality assessment on 8 Out of 14 QUADAS questions for each included study

STUDY ID | Q1: Spectrum | Q2. Selection criteria | Q5. Reference standard? | Q8. Details of index test described | Q10. Index test interpreted without knowledge of RS | Q12. Same clinical data available | Q13. Uninterpretable test results reported | Q14. Withdrawals explained | TOTAL (“YES”)
Jaffe 1996^301^ | yes | no | no | yes | yes | yes | No | no | 4
Netto 1993^302^ | yes | no | no | yes | yes | yes | No | no | 4
Citron 1996^303^ | no | yes | yes | yes | yes | no | No | no | 4
Hatzichristou 2002^304^ | yes | yes | no | yes | yes | yes | No | no | 5
Martinez-Jabaloyas 2006^305^ | yes | no | no | yes | yes | yes | no | no | 4
Acar 2004^306^ | unclear | no | no | yes | yes | yes | no | no | 3
Earle 2003^307^ | yes | no | no | yes | yes | yes | no | no | 4
Rhoden 2002^308^ | no | yes | no | yes | yes | no | no | no | 3
Bunch 2002^309^ | yes | yes | unclear | yes | yes | yes | no | no | 5
Fahmy 1999^310^ | yes | no | no | yes | yes | yes | no | no | 4
Buvat 1997 ^311^ | yes | no | no | yes | yes | yes | no | no | 4
Akpunonu 1994^312^ | unclear | yes | yes | yes | unclear | yes | no | yes | 5
Drinka 1993^313^ | no | yes | no | yes | yes | yes | no | yes | 5
Johnson 1992^314^ | yes | no | no | yes | yes | yes | no | no | 4
El-Sakka 2005^315^ | no | yes | no | yes | yes | yes | No | no | 4
Tsujimura 2005^316^ | yes | yes | no | yes | yes | yes | No | no | 5
Guay 1991^317^ | no | yes | no | yes | yes | no | No | no | 3
Forsberg 1990^318^ | yes | yes | no | yes | yes | yes | No | no | 5
Reyes-Vallejo 2006^319^ | no | yes | no | yes | yes | no | No | no | 3
El-Sakka 2006^320^ | no | yes | no | yes | yes | yes | No | no | 4
Hwang 2007^321^ | yes | no | no | yes | yes | yes | No | no | 4
Low 2006^322^ | yes | yes | no | yes | yes | yes | No | no | 5
Guay 2007^323^ | unclear | no | no | no | yes | yes | No | no | 2
Zohdy 2007^324^ | unclear | yes | yes | yes | unclear | yes | No | no | 4