# Appendix E. Additional Acknowledgments

## The UO-EPC gratefully acknowledges the following individuals who served on our Technical Expert Panel (TEP). Acknowledgment does not reflect endorsement of this report

James A. Talcott, M.D., S.M. Center for Outcomes Research Massachusetts General Hospital Cancer Center Boston, MA

Howard Fink, M.D., M.P.H. Center for Chronic Disease Outcomes Research VA Medical Center Minneapolis, MN

Jeremy Heaton, B.A., M.A.Sc., M.A. Department of Urology, Queen's University Kingston General Hospital Kingston, ON

Donald E. Casey Jr. M.D., M.P.H., M.B.A. Atlantic Health Morristown, NJ

J. Thomas Cross, M.D., M.P.H. MedStudy Corporation Inc. Colorado Springs, CO

Amir Qaseem, M.D., Ph.D., M.H.A. Department of Clinical Programs American College of Physicians Philadelphia, PA

Vincenzia Snow, M.D. Department of Clinical Programs American College of Physicians Philadelphia, PA

Steven Fox, M.D., M.P.H. EPC Program Task Order Officer Agency for Healthcare Research and Quality Rockville, MD

## The UO-EPC gratefully acknowledges the following individuals who reviewed the initial draft of this evidence report, and provided constructive feedback. Acknowledgements not reflect endorsement of this report

James A. Talcott, M.D., S.M. Center for Outcomes Research Massachusetts General Hospital Cancer Center Boston, MA

Jeremy Heaton, BA, M.A. Sc., MA., Department of Urology, Queen's University Kingston General Hospital Kingston, ON

Donald E. Casey Jr., M.D., M.P.H., M.B.A. Atlantic Health Morristown, NJ

J. Thomas Cross, M.D., M.P.H. MedStudy Corporation Inc. Colorado Springs, CO

Amir Qaseem, M.D., Ph.D., M.H.A. Department of Clinical Programs American College of Physicians Philadelphia, PA

Vincenzia Snow, M.D. Department of Clinical Programs American College of Physicians Philadelphia, PA

Dr. Drago K. Montague Center for Advanced Research in Human Reproduction Infertility and Sexual Function Cleveland Clinic, Cleveland, OH

Steven Fox, M.D., M.P.H. EPC Program Task Order Officer Agency for Healthcare Research and Quality Rockville, MD